# Technical Expert Panel Members and Affiliation

TEP Member | Affiliation
Amy C. Degnim, M.D. | Breast Clinic Gastroenterologic and General Surgery Mayo Clinic Rochester, Minnesota
Stephen B. Edge, M.D., F.A.C.S. | Department of Breast Surgery Roswell Park Cancer Institute Buffalo, New York
Jay R. Harris, M.D. | Department of Radiation Oncology Dana-Farber Cancer Center Institute Brigham and Women’s Hospital Boston, Massachusetts
Kelly K. Hunt, M.D., F.A.C.S. | Department of Surgical Oncology The University of Texas MD Anderson Cancer Center Houston, Texas
Karla Kerlikowske, M.S., M.D. | Helen Diller Family Comprehensive Cancer Center University of California, San Francisco, VAMC San Francisco, California
Lee K. Tan, M.D. | Memorial Sloan-Kettering Cancer Center Sloan-Kettering Institute New York, New York
Eric P. Winer, M.D. | Breast Oncology Center Dana-Farber Cancer Institute Brigham and Women’s Hospital Boston, Massachusetts