# List of Excluded Studies

1 Two cases of breast cancer in young women. Eur J Surg Oncol. Feb. 1996;22(1):108-13. Case Reports. [pmid: 8846854].
2 Pathology of familial breast cancer: differences between breast cancers in carriers of BRCA1 or BRCA2 mutations and sporadic cases. Breast Cancer Linkage Consortium Lancet. May. 24. 1997;349(9064):1505-10. Not eligible level of evidence.
3 Image-detected breast cancer: state of the art diagnosis and treatment. International Breast Cancer Consensus Conference. J Am Coll Surg. Sep. 2001;193(3):297-302. Consensus. [pmid: 11548800].
4 Body fatness during childhood and adolescence and incidence of breast cancer in premenopausal women: a prospective cohort study. 2005. Not eligible outcomes.
5 Letrozole improves disease-free survival vs tamoxifen in adjuvant treatment of early breast cancer. Oncology (Williston Park). Mar. 2005;19(3):277. 360. Not eligible target population. [pmid: 15828547].
6 Zoledronic acid prevents cancer treatment-induced bone loss. Oncology (Williston Park). Mar. 2005;19(3):390. Not eligible target population. [pmid: 15828553].
7 Patient education. Ductal carcinoma in situ. Aust Fam Physician. Nov. 2005;34(11):955. Secondary data. [pmid: 16299631].
8 NSABP B-39, RTOG 0413: A Randomized Phase III Study of conventional whole breast irradiation versus partial breast irradiation for women with stage 0, I, or II breast cancer. Clin Adv Hematol Oncol. Oct. 2006;4(10):719-21. News. [pmid: 17111558].
9 Travis, et al. Cumulative Absolute Breast Cancer Risk for Young Women Treated for Hodgkin Lymphoma. JNCI. 2007;97(19):1428. Not eligible outcomes. [pmid: 16204692].
10 Diorio, et al. Insulin-Like Growth Factor-I, IGF-Binding Protein-3, and Mammographic Breast Density. Cancer. 2007;14(5):1065. Not eligible outcomes.
11 Michels, et al. Type 2 Diabetes and Subsequent Incidence of Breast Cancer in the Nurses’ Health Study. 2007;26(6):1752. Not eligible outcomes.
12 Mantzoros, et al. Adiponectin and Breast Cancer Risk. Journal of Clinical Endocrinology & Metabolism. 2007;89(3):1102. Not eligible outcomes. [pmid: 15001594].
13 Risk of Subsequent Breast Cancer in Relation to Characteristics of Screening Mammograms from Women Less Than 50 Years of Age. 2007. Not eligible outcomes.
14 Freudenheim, et al. Diet and alcohol consumption in relation to p53 mutations in breast tumors. Carcinogenesis. 2007;25(6):931. Not eligible outcomes. [pmid: 14742318].
15 Rohan, et al. p53 Alterations and Protein Accumulation in Benign Breast Tissue and Breast Cancer Risk: A Cohort Study. 2007;15(7). Not eligible outcomes.
16 Ziogas, et al. Cancer Risk Estimates for Family Members of a Population-based Family Registry for Breast and Ovarian Cancer. 2007;9. Not eligible outcomes.
17 Lewis, et al. Promoter Hypermethylation in Benign Breast Epithelium in Relation to Predicted Breast Cancer Risk. 2007;11(1):166. Not eligible outcomes.
18 XRCC1 Genotype and Breast Cancer: Functional Studies and Epidemiologic Data Show Interactions between XRCC1 Codon 280 His and. 2007. Not eligible outcomes.
19 Byrne, et al. Plasma Insulin-like Growth Factor (IGF) I, IGF-binding Protein 3, and Mammographic Density. 2007;60(14):3744. Not eligible outcomes.
20 Jonas, et al. Dietary Glycemic Index, Glycemic Load, and Risk of Incident Breast Cancer in Postmenopausal Women. 2007;12(6):573. Not eligible outcomes.
21 Horn-Ross, et al. Patterns of Alcohol Consumption and Breast Cancer Risk in the California Teachers Study Cohort. 2007;13(3):405. Not eligible outcomes.
22 Vacek, Geller. A Prospective Study of Breast Cancer Risk Using Routine Mammographic Breast Density Measurements. 2007;13(5). Not eligible outcomes.
23 Genetic Polymorphisms in the IGFBP3 Gene: Association with Breast Cancer Risk and Blood IGFBP-3 Protein Levels among Chinese. 2007. Not eligible outcomes.
24 Atkinson, et al. Mammographic Patterns as a Predictive Biomarker of Breast Cancer Risk: Effect of Tamoxifen. 2007;8(10):863. Not eligible outcomes.
25 Cui, Rohan. Vitamin D, Calcium, and Breast Cancer Risk: A Review. Cancer Epidemiology Biomarkers. 2007;15(8):1427. Review.
26 Krajcik, et al. Insulin-like Growth Factor I (IGF-I), IGF-binding Proteins, and Breast Cancer. Cancer. 2007;11(12):1566. Not eligible outcomes.
27 Pala, et al. Erythrocyte Membrane Fatty Acids and Subsequent Breast Cancer: a Prospective Italian Study. JNCI. 2007;93(14):1088. Not eligible outcomes. [pmid: 11459870].
28 Egan a, et al. STK15 polymorphism and breast cancer risk in a population-based study. Carcinogenesis. 2007;25(11):2149. Not eligible outcomes. [pmid: 15271853].
29 A Haplotype Analysis of HER-2 Gene Polymorphisms: Association with Breast Cancer Risk, HER-2 Protein Expression in the Tumor. 2007. Not eligible outcomes.
30 Yu, et al. Insulin-like Growth Factors and Breast Cancer Risk in Chinese Women. Cancer Epidemiology Biomarkers. 2007;11(8):705. Not eligible outcomes.
31 Tehard, et al. Effect of Physical Activity on Women at Increased Risk of Breast Cancer: Results from the E3N Cohort Study. 2007;15. Not eligible outcomes.
32 Association of BRCA2 Polymorphism at Codon 784 (Met/Val) with Breast. 2007. Not eligible outcomes.
33 Gammon, et al. Cigarette Smoking and Other Risk Factors in Relation to p53 Expression in Breast Cancer among Young Women. 2007;8. Not eligible outcomes.
34 Understanding ductal carcinoma in situ. Most women diagnosed with this noninvasive breast cancer are alive 10 years later, and better treatments are emerging. Harv Womens Health Watch. Oct. 2008;16(2):1-3. Comment.
35 Kerlikowske, et al. Are Breast Density and Bone Mineral Density Independent Risk Factors for Breast Cancer?. 2008;97(5):368. Not eligible outcomes.
36 Role of Physical Activity in Modulating Breast Cancer Risk as Defined by APC and RASSF1A Promoter Hypermethylation in. 2008. Not eligible outcomes.
37 Vachon, et al. Longitudinal Trends in Mammographic Percent Density and Breast Cancer Risk. Cancer Epidemiology. 2008;16(5):921. Not eligible outcomes.
38 Hypermethylation of the Breast Cancer-Associated Gene 1 Promoter Does Not Predict Cytologic Atypia or Correlate with Surrogate. 2008. Not eligible outcomes.
39 Aaltomaa S, Lipponen P, Papinaho S, et al. Nuclear morphometry and DNA flow cytometry as prognostic factors in female breast cancer. Eur J Surg. Mar. 1992;158(3):135-41. Not eligible target population. [pmid: 1356452].
40 Aasmundstad TA, Haugen OA. DNA ploidy in intraductal breast carcinomas. Eur J Cancer. 1990;26(9):956-9. Not eligible outcomes. [pmid: 2177615].
41 Abati AD, Kimmel M, Rosen PP. Apocrine mammary carcinoma. A clinicopathologic study of 72 cases. Am J Clin Pathol. Oct. 1990;94(4):371-7. Not eligible target population. [pmid: 2171320].
42 Abdel-Fatah TM, Powe DG, Hodi Z, et al. High frequency of coexistence of columnar cell lesions, lobular neoplasia, and low grade ductal carcinoma in situ with invasive tubular carcinoma and invasive lobular carcinoma. Am J Surg Pathol. Mar. 2007;31(3):417-26. Not eligible outcomes. [pmid: 17325484].
43 Abe H, Schmidt RA, Kulkarni K, et al. Axillary lymph nodes suspicious for breast cancer metastasis: sampling with US-guided 14-gauge core-needle biopsy--clinical experience in 100 patients. Radiology. Jan. 2009;250(1):41-9. Not eligible target population. [pmid: 18955508].
44 Abedi K, Salazar L, Raneri AJ, et al. Aberrant breast carcinoma: case report and review of the literature. Md State Med J. May. 1979;28(5):55-6. Case Reports. [pmid: 220471].
45 Abendroth CS, Wang HH, Ducatman BS. Comparative features of carcinoma in situ and atypical ductal hyperplasia of the breast on fine-needle aspiration biopsy specimens. Am J Clin Pathol. Nov. 1991;96(5):654-9. Not eligible outcomes. [pmid: 1659182].
46 Aboulafia DM. Carcinocythemia. A terminal manifestation of metastatic breast cancer. West J Med. Dec. 1992;157(6):672-4. Case Reports. [pmid: 1335633].
47 Abraham SC, Fox K, Fraker D, et al. Sampling of grossly benign breast reexcisions: a multidisciplinary approach to assessing adequacy. Am J Surg Pathol. Mar. 1999;23(3):316-22. Not eligible outcomes. [pmid: 10078923].
48 Acs G, Lawton TJ, Rebbeck TR, et al. Differential expression of E-cadherin in lobular and ductal neoplasms of the breast and its biologic and diagnostic implications. Am J Clin Pathol. Jan. 2001;115(1):85-98. Not eligible outcomes. [pmid: 11190811].
49 Adams AH, Brookeman JR, Merickel MB. Breast lesion discrimination using statistical analysis and shape measures on magnetic resonance imagery. Comput Med Imaging Graph. Sep–Oct. 1991;15(5):339-49. Not eligible outcomes. [pmid: 1661638].
50 Adams-Cameron M, Gilliland FD, Hunt WC, et al. Trends in incidence and treatment for ductal carcinoma in situ in Hispanic, American Indian, and non-Hispanic white women in New Mexico, 1973-1994. Cancer. Mar. 1. 1999;85(5):1084-90. Not eligible outcomes. [pmid: 10091792].
51 Adebamowo CA, Akang EE, Ezeome ER. Carcinoma of the breast in a sickle cell disease patient: case report. East Afr Med J. Jul. 1996;73(7):489-90. Case Reports. [pmid: 8918018].
52 Adem C, Soderberg CL, Cunningham JM, et al. Microsatellite instability in hereditary and sporadic breast cancers. Int J Cancer. Nov. 20. 2003;107(4):580-2. Not eligible outcomes. [pmid: 14520695].
53 Adeyinka A, Emberley E, Niu Y, et al. Analysis of gene expression in ductal carcinoma in situ of the breast. Clin Cancer Res. Dec. 2002;8(12):3788-95. Not eligible outcomes. [pmid: 12473591].
54 Adler OB, Engel A. Mammographic wire-guided biopsies in non-palpable breast lesions. Eur J Radiol. May. 1989;9(2):108-11. Not eligible outcomes. [pmid: 2545445].
55 Adrales G, Turk P, Wallace T, et al. Is surgical excision necessary for atypical ductal hyperplasia of the breast diagnosed by Mammotome. Am J Surg. Oct. 2000;180(4):313-5. Not eligible outcomes. [pmid: 11113443].
56 Afify A, Bland KI, Mark HF. Fluorescent in situ hybridization assessment of chromosome 8 copy number in breast cancer. Breast Cancer Res Treat. 1996;38(2):201-8. Not eligible outcomes. [pmid: 8861838].
57 Agarwal B, Saxena R, Morimiya A, et al. Lymphangiogenesis does not occur in breast cancer. Am J Surg Pathol. Nov. 2005;29(11):1449-55. Not eligible outcomes. [pmid: 16224211].
58 Agarwal T, Patel B, Rajan P, et al. Core biopsy versus FNAC for palpable breast cancers. Is image guidance necessary?. Eur J Cancer. Jan. 2003;39(1):52-6. Not eligible outcomes. [pmid: 12504658].
59 Agelopoulos K, Buerger H, Brandt B. Allelic imbalances of the egfr gene as key events in breast cancer progression--the concept of committed progenitor cells. Curr Cancer Drug Targets. Aug. 2008;8(5):431-45. Review. [pmid: 18690849].
60 Ahern V, Soo YS, Langlands AD. MRI scanning in brachial plexus neuropathy. Australas Radiol. Nov. 1991;35(4):379-81. Case Reports. [pmid: 1667466].
61 Ahmad A, Hanby A, Dublin E, et al. Stromelysin 3: an independent prognostic factor for relapse-free survival in node-positive breast cancer and demonstration of novel breast carcinoma cell expression. Am J Pathol. Mar. 1998;152(3):721-8. Not eligible target population. [pmid: 9502414].
62 Aisner J. Breast cancer therapy in the elderly. JAMA. Jul. 21. 1993;270(3):391. Case Reports. [pmid: 8391087].
63 Aistars J, Vehlow K. Radiation dermatitis. Oncology (Williston Park). Jul. 2007;21(8 Suppl):41-3. Case Reports. [pmid: 17844895].
64 Ajisaka H, Tsugawa K, Noguch M, et al. Histological subtypes of ductal carcinoma in situ of the breast. Breast Cancer. 2002;9(1):55-61. Not eligible outcomes. [pmid: 12196723].
65 Aktan AO, Gokoz A, Goksel H. Paget’s disease without a palpable mass in the breast. Br J Surg. Feb. 1990;77(2):226-7. Not eligible target population. [pmid: 2156593].
66 Al-Ahmadie H, Hasselgren PO, Yassin R, et al. Colocalized granular cell tumor and infiltrating ductal carcinoma of the breast. Arch Pathol Lab Med. Jun. 2002;126(6):731-3. Case Reports. [pmid: 12033967].
67 Alamo L, Fischer U. Contrast-enhanced color Doppler ultrasound characteristics in hypervascular breast tumors: comparison with MRI. Eur Radiol. 2001;11(6):970-7. Not eligible outcomes. [pmid: 11419173].
68 Al-Attar MA, Michell MJ, Ralleigh G, et al. The impact of image guided needle biopsy on the outcome of mammographically detected indeterminate microcalcification. Breast. Oct. 2006;15(5):635-9. Not eligible outcomes. [pmid: 16488148].
69 Albert MP, Sachsse E, Coe NP, et al. Correlation between mammography and the pathology of nonpalpable breast lesions. J Surg Oncol. May. 1990;44(1):44-6. Not eligible outcomes. [pmid: 2342374].
70 Albonico G, Querzoli P, Ferretti S, et al. Biological heterogeneity of breast carcinoma in situ. Ann N Y Acad Sci. Apr. 30. 458. 1996:784-61. Not eligible outcomes.
71 Albonico G, Querzoli P, Ferretti S, et al. Biological profile of in situ breast cancer investigated by immunohistochemical technique. Cancer Detect Prev. 1998;22(4):313-8. Not eligible outcomes. [pmid: 9674874].
72 Aldaz CM, Chen T, Sahin A, et al. Comparative allelotype of in situ and invasive human breast cancer: high frequency of microsatellite instability in lobular breast carcinomas. Cancer Res. Sep. 15. 1995;55(18):3976-81. Not eligible outcomes. [pmid: 7664266].
73 Alderman AK, McMahon L Jr, Wilkins EG. The national utilization of immediate and early delayed breast reconstruction and the effect of sociodemographic factors. Plast Reconstr Surg. Feb. 2003;111(2):695-703. discussion 4-5. Not eligible outcomes. [pmid: 12560690].
74 Alexander H, Stegner AL, Wagner-Mann C, et al. Proteomic analysis to identify breast cancer biomarkers in nipple aspirate fluid. Clin Cancer Res. Nov. 15. 2004;10(22):7500-10. Not eligible outcomes. [pmid: 15569980].
75 Alexander MC, Yankaskas BC, Biesemier KW. Association of stellate mammographic pattern with survival in small invasive breast tumors. AJR Am J Roentgenol. Jul. 2006;187(1):29-37. Not eligible target population. [pmid: 16794151].
76 Al-Hallaq HA, Mell LK, Bradley JA, et al. Magnetic resonance imaging identifies multifocal and multicentric disease in breast cancer patients who are eligible for partial breast irradiation. Cancer. Nov. 1. 2008;113(9):2408-14. Not eligible target population. [pmid: 18823018].
77 al-Idrissi HY. Pattern of breast cancer in Saudi females in eastern province of Saudi Arabia. Indian J Med Sci. Apr. 1991;45(4):85-7. Not eligible target population. [pmid: 1660447].
78 Ali-Fehmi R, Carolin K, Wallis T, et al. Clinicopathologic analysis of breast lesions associated with multiple papillomas. Hum Pathol. Mar. 2003;34(3):234-9. Case Reports. [pmid: 12673557].
79 Al-Joudi FS, Iskandar ZA, Rusli J. The expression of p53 in invasive ductal carcinoma of the breast: a study in the North-East States of Malaysia. Med J Malaysia. Jun. 2008;63(2):96-9. Not eligible target population. [pmid: 18942291].
80 Allan SM, Dean CJ, Eccles S, et al. Clinical radioimmunolocalization with a rat monoclonal antibody directed against c-erbB-2. Cell Biophys. 1994:24-25. 93. 8. Not eligible outcomes.
81 Alonso-Munoz MC, Ojeda-Gonzalez MB, Beltran-Fabregat M, et al. Randomized trial of tamoxifen versus aminoglutethimide and versus combined tamoxifen and aminoglutethimide in advanced postmenopausal breast cancer. Oncology. 1988;45(5):350-3. Not eligible target population. [pmid: 3045726].
82 Alowami S, Troup S, Al-Haddad S, et al. Mammographic density is related to stroma and stromal proteoglycan expression. Breast Cancer Res. 2003;5(5):R129-35. Not eligible target population. [pmid: 12927043].
83 Altundag K, Bulut N, Sari E, et al. The role of aromatase inhibitors in the management of ductal carcinoma in situ with an estrogen receptor-positive/progesterone receptor-negative/Her-2/neu receptor-positive pattern. Am J Surg. Aug. 2007;194(2):272-3. No primary data. [pmid: 17618822].
84 Amano G, Ohuchi N, Ishibashi T, et al. Correlation of three-dimensional magnetic resonance imaging with precise histopathological map concerning carcinoma extension in the breast. Breast Cancer Res Treat. Mar. 2000;60(1):43-55. Not eligible target population. [pmid: 10845808].
85 Amano G, Yajima M, Moroboshi Y, et al. MRI accurately depicts underlying DCIS in a patient with Paget’s disease of the breast without palpable mass and mammography findings. Jpn J Clin Oncol. Mar. 2005;35(3):149-53. Case Reports. [pmid: 15741305].
86 Amari M, Moriya T, Ishida T, et al. Loss of heterozygosity analyses of asynchronous lesions of ductal carcinoma in situ and invasive ductal carcinoma of the human breast. Jpn J Clin Oncol. Nov. 2003;33(11):556-62. Not eligible outcomes. [pmid: 14711979].
87 Amari M, Suzuki A, Moriya T, et al. LOH analyses of premalignant and malignant lesions of human breast: frequent LOH in 8p, 16q, and 17q in atypical ductal hyperplasia. Oncol Rep. Nov–Dec. 1999;6(6):1277-80. Not eligible outcomes. [pmid: 10523696].
88 Amat S, Penault-Llorca F, Cure H, et al. Scarff-Bloom-Richardson (SBR) grading: a pleiotropic marker of chemosensitivity in invasive ductal breast carcinomas treated by neoadjuvant chemotherapy. Int J Oncol. Apr. 2002;20(4):791-6. Not eligible target population. [pmid: 11894126].
89 Amenta PS, Hadad S, Lee MT, et al. Loss of types XV and XIX collagen precedes basement membrane invasion in ductal carcinoma of the female breast. J Pathol. Mar. 2003;199(3):298-308. Not eligible outcomes. [pmid: 12579531].
90 Amin SA, Huang CC, Reierstad S, et al. Paracrine-stimulated gene expression profile favors estradiol production in breast tumors. Mol Cell Endocrinol. Jul. 11. 1. 2006:253-2. 44. 55. Not eligible outcomes.
91 Amir J, Atkinson WE, McDonald JE, et al. Breast cancer metastatic to the lung. J Ark Med Soc. Jan. 1990;86(8):320-1. Case Reports. [pmid: 2154444].
92 An HJ, Kim NK, Oh D, et al. Her2 genotype and breast cancer progression in Korean women. Pathol Int. Feb. 2005;55(2):48-52. Not eligible target population. [pmid: 15693849].
93 An T, Grathwohl M, Frable WJ. Breast carcinoma with osseous metaplasia: an electron microscopic study. Am J Clin Pathol. Jan. 1984;81(1):127-32. Case Reports. [pmid: 6318548].
94 Ana JN, Thompson SG, Williams MV, et al. Survival with metastatic breast cancer for 24 years. Eur J Surg. Apr. 1993;159(4):239-40. Case Reports. [pmid: 8102546].
95 Anan K, Mitsuyama S, Tamae K, et al. Tubular carcinoma of the breast: a histologic subtype indicative of breast-conserving therapy. Surg Today. 2000;30(12):1057-61. Not eligible target population. [pmid: 11193735].
96 Anan K, Mitsuyama S, Tamae K, et al. Increased dihydropyrimidine dehydrogenase activity in breast cancer. J Surg Oncol. Mar. 2003;82(3):174-9. Not eligible outcomes. [pmid: 12619061].
97 Anan K, Morisaki T, Katano M, et al. Preoperative assessment of tumor angiogenesis by vascular endothelial growth factor mRNA expression in homogenate samples of breast carcinoma: fine-needle aspirates vs. resection samples. J Surg Oncol. Dec. 1997;66(4):257-63. Not eligible outcomes. [pmid: 9425330].
98 Anastassiades OT, Tsakraklides E, Gogas J. The histology of fibrocystic disease of the female breast. Correlation with epithelial proliferative lesions and carcinoma in situ. Pathol Res Pract. Jul. 1. 1981:172-2. 109. 29. Not eligible outcomes.
99 Andersen JA, Pallesen RM. Spread to the nipple and areola in carcinoma of the breast. Ann Surg. Mar. 1979;189(3):367-72. Not eligible outcomes. [pmid: 218505].
100 Anderson C, Muller R, Piorkowski R, et al. Intraductal carcinoma of major salivary gland. Cancer. Feb. 1. 1992;69(3):609-14. Case Reports. [pmid: 1309674].
101 Anderson GL, Chlebowski RT, Rossouw JE, et al. Prior hormone therapy and breast cancer risk in the Women’s Health Initiative randomized trial of estrogen plus progestin. Maturitas. Sep. 20. 2006;55(2):103-15. Not eligible outcomes. [pmid: 16815651].
102 Anderson NH, Hamilton PW, Bartels PH, et al. Computerized scene segmentation for the discrimination of architectural features in ductal proliferative lesions of the breast. J Pathol. Apr. 1997;181(4):374-80. Not eligible outcomes. [pmid: 9196433].
103 Anderson TJ, Dixon JM, Stuart M, et al. Effect of neoadjuvant treatment with anastrozole on tumour histology in postmenopausal women with large operable breast cancer. Br J Cancer. Jul. 29. 2002;87(3):334-8. Not eligible target population. [pmid: 12177804].
104 Anderson WR. Bilateral Paget’s disease of the nipple: case report. Am J Obstet Gynecol. Aug. 15. 1979;134(8):877-8. Not eligible target population. [pmid: 223445].
105 Andersson I, Janzon L, Sigfusson BF. Mammographic breast cancer screening--a randomized trial in Malmo, Sweden. Maturitas. May. 1985;7(1):21-9. Not eligible outcomes. [pmid: 2991708].
106 Ando Y, Iwase H, Ichihara S, et al. Loss of heterozygosity and microsatellite instability in ductal carcinoma in situ of the breast. Cancer Lett. Aug. 11. 2000;156(2):207-14. Not eligible outcomes. [pmid: 10880771].
107 Andreu FJ, Saez A, Sentis M, et al. Breast core biopsy reporting categories--An internal validation in a series of 3054 consecutive lesions. Breast. Feb. 2007;16(1):94-101. Not eligible target population. [pmid: 16982194].
108 Angele S, Treilleux I, Bremond A, et al. Altered expression of DNA double-strand break detection and repair proteins in breast carcinomas. Histopathology. Oct. 2003;43(4):347-53. Not eligible outcomes. [pmid: 14511253].
109 Anjum S, Khan S, Baig SM, et al. Effect of chemotherapy on circulating steroid hormone levels in postoperative premenopausal breast cancer patients. J Pak Med Assoc. Dec. 1991;41(12):296-8. Not eligible target population. [pmid: 1663170].
110 Ansari B, Purdie CA, Brown DC. Adult Langerhans cell histiocytosis mimicking Paget’s disease of the nipple. Breast J. Jul–Aug. 2005;11(4):281-2. Not eligible target population. [pmid: 15982397].
111 Anthuber M, Kemkes BM, Gokel M, et al. Carcinoma of the breast and heart transplantation: a case report. J Heart Lung Transplant. Sep–Oct. 1991;10(5 Pt 1):782-3. Case Reports. [pmid: 1659904].
112 Apesteguia L, Mellado M, Saenz J, et al. Vacuum-assisted breast biopsy on digital stereotaxic table of nonpalpable lesions non-recognisable by ultrasonography. Eur Radiol. Mar. 2002;12(3):638-45. Not eligible outcomes. [pmid: 11870480].
113 Apple SK. Variability in gross and microscopic pathology reporting in excisional biopsies of breast cancer tissue. Breast J. Mar–Apr. 2006;12(2):145-9. Not eligible outcomes. [pmid: 16509839].
114 Archili C, Lissoni P, Cattaneo G, et al. Lack of changes in soluble interleukin-2 receptor serum levels during chemotherapy-induced lymphocyte damage. Int J Biol Markers. Jan–Mar. 1990;5(1):43-5. Not eligible target population. [pmid: 2172411].
115 Argenta LC. Simulated metastatic carcinoma after breast reconstruction. Am J Surg. Feb. 1985;149(2):299-300. Case Reports. [pmid: 2982291].
116 Ariad S, Seymour L, Bezwoda WR. Platelet-derived growth factor (PDGF) in plasma of breast cancer patients: correlation with stage and rate of progression. Breast Cancer Res Treat. Dec. 1991;20(1):11-7. Not eligible outcomes. [pmid: 1667486].
117 Ariga N, Moriya T, Suzuki T, et al. Retinoic acid receptor and retinoid X receptor in ductal carcinoma in situ and intraductal proliferative lesions of the human breast. Jpn J Cancer Res. Nov. 2000;91(11):1169-76. Not eligible outcomes. [pmid: 11092983].
118 Ariga N, Moriya T, Suzuki T, et al. 17 beta-Hydroxysteroid dehydrogenase type 1 and type 2 in ductal carcinoma in situ and intraductal proliferative lesions of the human breast. Anticancer Res. Mar–Apr. 2000;20(2B):1101-8. Not eligible outcomes. [pmid: 10810403].
119 Ariga R, Bloom K, Reddy VB, et al. Fine-needle aspiration of clinically suspicious palpable breast masses with histopathologic correlation. Am J Surg. Nov. 2002;184(5):410-3. Not eligible outcomes. [pmid: 12433603].
120 Arihiro K, Inai K, Kurihara K, et al. Loss of VLA-2 collagen receptor in breast carcinoma, facilitating invasion and metastasis. Jpn J Cancer Res. Jul. 1993;84(7):726-33. Not eligible outcomes. [pmid: 8396565].
121 Arnold RE, Frykberg ER, Kilkenny JW 3rd, et al. Trends in surgical treatment of breast cancer at an urban teaching hospital: a six-year review. Am Surg. Feb. 1998;64(2):107-11. Not eligible outcomes. [pmid: 9486879].
122 Arora S, Menes TS, Moung C, et al. Atypical ductal hyperplasia at margin of breast biopsy--is re-excision indicated?. Annals of Surgical Oncology. Mar. 2008;15(3):843-7. Not eligible target population. [pmid: 17987337].
123 Arpino G, Allred DC, Mohsin SK, et al. Lobular neoplasia on core-needle biopsy--clinical significance. Cancer. Jul. 15. 2004;101(2):242-50. Not eligible target population. [pmid: 15241819].
124 Arpino G, Laucirica R, Elledge RM. Premalignant and in situ breast disease: biology and clinical implications. Ann Intern Med. Sep. 20. 2005;143(6):446-57. Review. [pmid: 16172443].
125 Arthur DW, Koo D, Zwicker RD, et al. Partial breast brachytherapy after lumpectomy: low-dose-rate and high-dose-rate experience. Int J Radiat Oncol Biol Phys. Jul. 1. 2003;56(3):681-9. Not eligible target population. [pmid: 12788173].
126 Arun B, Vogel KJ, Lopez A, et al. High Prevalence of Preinvasive Lesions Adjacent to BRCA1/2-Associated Breast Cancers. Cancer Prev Res (Phila Pa). 2009. Jan. 27. Not eligible level of evidence.
127 Aryal KR, Lengyel AJ, Purser N, et al. Nipple core biopsy for the deformed or scaling nipple. Breast. Aug. 2004;13(4):350-2. Not eligible target population. [pmid: 15325673].
128 Ascenso AC, Marques MS, Capitao-Mor M. Paget’s disease of the nipple. Clinical and pathological review of 109 female patients. Dermatologica. 1985;170(4):170-9. Not eligible target population. [pmid: 2987049].
129 Asch HL, Winston JS, Edge SB, et al. Down-regulation of gelsolin expression in human breast ductal carcinoma in situ with and without invasion. Breast Cancer Res Treat. May. 1999;55(2):179-88. Not eligible outcomes. [pmid: 10481945].
130 Ascunce N, Del Moral A, Murillo A, et al. Early detection programme for breast cancer in Navarra, Spain. Eur J Cancer Prev. 1994;01; 3(Suppl 1):41-8. Not eligible outcomes.
131 Ashworth MT, Haqqani MT. Endocrine variant of ductal carcinoma in situ of breast: ultrastructural and light microscopical study. J Clin Pathol. Dec. 1986;39(12):1355-9. Case Reports. [pmid: 2433311].
132 Assersohn L, Gangi L, Zhao Y, et al. The feasibility of using fine needle aspiration from primary breast cancers for cDNA microarray analyses. Clin Cancer Res. Mar. 2002;8(3):794-801. Not eligible target population. [pmid: 11895911].
133 Assersohn L, Powles TJ, Ashley S, et al. Local relapse in primary breast cancer patients with unexcised positive surgical margins after lumpectomy, radiotherapy and chemoendocrine therapy. Ann Oncol. Dec. 1999;10(12):1451-5. Not eligible target population. [pmid: 10643535].
134 Atalay G, Dirix L, Biganzoli L, et al. The effect of exemestane on serum lipid profile in postmenopausal women with metastatic breast cancer: a companion study to EORTC Trial 10951, ‘Randomized phase II study in first line hormonal treatment for metastatic breast cancer with exemestane or tamoxifen in postmenopausal patients’. Ann Oncol. Feb. 2004;15(2):211-7. Not eligible target population. [pmid: 14760111].
135 Athanasiou A, Vanel D, Fournier L, et al. Optical mammography: a new technique for visualizing breast lesions in women presenting non palpable BIRADS 4-5 imaging findings: preliminary results with radiologic-pathologic correlation. Cancer Imaging. 2007;7:34-40. Not eligible outcomes. [pmid: 17339139].
136 Athow AC, Gattuso JM, Perry N, et al. Is radiotherapy needed after breast conservation for small invasive breast cancers. Eur J Surg Oncol. Jun. 2002;28(4):379-82. Not eligible target population. [pmid: 12099645].
137 Atlante G, Pozzi M, Vincenzoni C, et al. Four case reports presenting new acquisitions on the association between breast and endometrial carcinoma. Gynecol Oncol. Jun. 1990;37(3):378-80. Case Reports. [pmid: 2161782].
138 Aubele M, Cummings M, Walsch A, et al. Heterogeneous chromosomal aberrations in intraductal breast lesions adjacent to invasive carcinoma. Anal Cell Pathol. 2000;20(1):17-24. Not eligible outcomes. [pmid: 11007434].
139 Aubele M, Mattis A, Zitzelsberger H, et al. Extensive ductal carcinoma In situ with small foci of invasive ductal carcinoma: evidence of genetic resemblance by CGH. Int J Cancer. Jan. 1. 2000;85(1):82-6. Not eligible target population. [pmid: 10585588].
140 Aulmann S, Bentz M, Sinn HP. C-myc oncogene amplification in ductal carcinoma in situ of the breast. Breast Cancer Res Treat. Jul. 2002;74(1):25-31. Not eligible outcomes. [pmid: 12150449].
141 Avisar E, Molina MA, Scarlata M, et al. Internal mammary sentinel node biopsy for breast cancer. American Journal of Surgery. Oct. 2008;196(4):490-4. Not eligible outcomes. [pmid: 18723148].
142 Avril N, Menzel M, Dose J, et al. Glucose metabolism of breast cancer assessed by 18F-FDG PET: histologic and immunohistochemical tissue analysis. J Nucl Med. Jan. 2001;42(1):9-16. Not eligible outcomes. [pmid: 11197987].
143 Axelrod DE, Miller NA, Lickley HL, et al. Effect of Quantitative Nuclear Image Features on Recurrence of Ductal Carcinoma In Situ (DCIS) of the Breast. Cancer Inform. 2008;6:99-109. Not eligible level of evidence. [pmid: 18779878].
144 Aziz D, Rawlinson E, Narod SA, et al. The role of reexcision for positive margins in optimizing local disease control after breast-conserving surgery for cancer. Breast J. Jul–Aug. 2006;12(4):331-7. Not eligible target population. [pmid: 16848842].
145 Azria D, Auvray H, Barillot I, et al. Ductal carcinoma in situ: role of the boost. Cancer Radiother. Nov. 6. 2008:12-7. 571. 6. Language.
146 Azuma A, Tozaki M, Ito K, et al. Ductal carcinoma in situ: correlation between FDG-PET/CT and histopathology. Radiat Med. Oct. 2008;26(8):488-93. Not eligible outcomes. [pmid: 18975050].
147 Azzopardi JG, Muretto P, Goddeeris P, et al. ‘Carcinoid’ tumours of the breast: the morphological spectrum of argyrophil carcinomas. Histopathology. Sep. 1982;6(5):549-69. Not eligible target population. [pmid: 6183185].
148 Baak JP, Chin D, van Diest PJ, et al. Comparative long-term prognostic value of quantitative HER-2/neu protein expression, DNA ploidy, and morphometric and clinical features in paraffin-embedded invasive breast cancer. Lab Invest. Feb. 1991;64(2):215-23. Not eligible target population. [pmid: 1671789].
149 Baak JP, Wisse-Brekelmans EC, Kurver PH, et al. Regional differences in breast cancer survival are correlated with differences in differentiation and rate of proliferation. Hum Pathol. Sep. 1992;23(9):989-92. Not eligible target population. [pmid: 1325412].
150 Bachmeier BE, Nerlich AG, Mirisola V, et al. Lineage infidelity and expression of melanocytic markers in human breast cancer. Int J Oncol. Nov. 2008;33(5):1011-5. Not eligible outcomes. [pmid: 18949364].
151 Bacus SS, Bacus JW, Slamon DJ, et al. HER-2/neu oncogene expression and DNA ploidy analysis in breast cancer. Arch Pathol Lab Med. Feb. 1990;114(2):164-9. Not eligible outcomes. [pmid: 1967930].
152 Badejo OA. Fungating accessory breast carcinoma in Nigerian women. Trop Geogr Med. Mar. 1984;36(1):45-9. Case Reports. [pmid: 6328710].
153 Badoual C, Maruani A, Ghorra C, et al. Pathological prognostic factors of invasive breast carcinoma in ultrasound-guided large core biopsies-correlation with subsequent surgical excisions. Breast. Feb. 2005;14(1):22-7. Not eligible outcomes. [pmid: 15695077].
154 Badra FA, Karamouzis MV, Ravazoula P, et al. Non-palpable breast carcinomas: correlation of mammographically detected malignant-appearing microcalcifications and epidermal growth factor receptor (EGFR) family expression. Cancer Lett. Nov. 28. 2006;244(1):34-41. Not eligible outcomes. [pmid: 16517064].
155 Badve S, Turbin D, Thorat MA, et al. FOXA1 expression in breast cancer--correlation with luminal subtype A and survival. Clin Cancer Res. Aug. 1. 2007;13(15 Pt 1):4415-21. Not eligible target population. [pmid: 17671124].
156 Baek IS, Jeong AC, Lee SB, et al. A case of intraductal papillary tumor of pancreas associated with mucinous ductal ectasia. Korean J Intern Med. Jan. 1997;12(1):100-4. Case Reports. [pmid: 9159048].
157 Baggott JE, Heimburger DC, Krumdieck CL, et al. Folate conjugase activity in the plasma and tumors of breast-cancer patients. Am J Clin Nutr. Aug. 1987;46(2):295-301. Not eligible outcomes. [pmid: 3039825].
158 Bagnall MJ, Evans AJ, Wilson AR, et al. Predicting invasion in mammographically detected microcalcification. Clin Radiol. Oct. 2001;56(10):828-32. Not eligible outcomes. [pmid: 11895299].
159 Bagnera S, Campanino P, Barisone F, et al. Imaging, histology and hormonal features of five cases of male breast cancer observed in a single year: comparison with the literature. Radiol Med. Dec. 2008;113(8):1096-109. Not eligible target population. [pmid: 18836815].
160 Baildam AD. The role of bilateral prophylactic mastectomy (BPMX) in women at high risk of breast cancer. Dis Markers. Oct. 1. 1999:15-3. 197. 8. Comment.
161 Baird RM, Worth A, Hislop G. Recurrence after lumpectomy for comedo-type intraductal carcinoma of the breast. Am J Surg. May. 1990;159(5):479-81. Not eligible level of evidence. [pmid: 2159245].
162 Bajetta E, Ferrari L, Celio L, et al. The aromatase inhibitor letrozole in advanced breast cancer: effects on serum insulin-like growth factor (IGF)-I and IGF-binding protein-3 levels. J Steroid Biochem Mol Biol. Nov–Dec. 1997;63:4-6. 261. 7. Not eligible target population.
163 Bajetta E, Zilembo N, Barni S, et al. A multicentre, randomized, pharmacokinetic, endocrine and clinical study to evaluate formestane in breast cancer patients at first relapse: endocrine and clinical results. The Italian Trials in Medical Oncology (I.T.M.O.) group. Ann Oncol. Jul. 1997;8(7):649-54. Not eligible target population. [pmid: 9296217].
164 Bajetta E, Zilembo N, Buzzoni R, et al. Endocrinological and clinical evaluation of two doses of formestane in advanced breast cancer. Br J Cancer. Jul. 1994;70(1):145-50. Not eligible target population. [pmid: 8018527].
165 Bajetta E, Zilembo N, Dowsett M, et al. Double-blind, randomised, multicentre endocrine trial comparing two letrozole doses, in postmenopausal breast cancer patients. Eur J Cancer. Feb. 1999;35(2):208-13. Not eligible target population. [pmid: 10448261].
166 Bajetta E, Zilembo N, Noberasco C. Second-generation aromatase inhibitors. Tumori. Mar–Apr. 1995;81(2):77-80. Not eligible target population. [pmid: 7778222].
167 Bajetta E, Zilembo N, Noberasco C, et al. The minimal effective exemestane dose for endocrine activity in advanced breast cancer. Eur J Cancer. Apr. 1997;33(4):587-91. Not eligible target population. [pmid: 9274439].
168 Baker KS, Monsees BS, Diaz NM, et al. Carcinoma within fibroadenomas: mammographic features. Radiology. Aug. 1990;176(2):371-4. Not eligible outcomes. [pmid: 2164233].
169 Baker RR. Unusual lesions and their management. Surg Clin North Am. Aug. 1990;70(4):963-75. Not eligible target population. [pmid: 2164716].
170 Balch GC, Mithani SK, Simpson JF, et al. Accuracy of intraoperative gross examination of surgical margin status in women undergoing partial mastectomy for breast malignancy. Am Surg. Jan. 2005;71(1):22-7. discussion 7-8. Not eligible level of evidence. [pmid: 15757052].
171 Balich SM, Khandekhar JD, Sener SF. Cancer of the male breast presenting as an axillary mass. J Surg Oncol. May. 1993;53(1):68-70. Case Reports. [pmid: 8386785].
172 Balleine RL, Murali R, Bilous AM, et al. Histopathological features of breast cancer in carriers of ATM gene variants. Histopathology. Nov. 2006;49(5):523-32. Not eligible outcomes. [pmid: 17064299].
173 Balleine RL, Webster LR, Davis S, et al. Molecular grading of ductal carcinoma in situ of the breast. Clin Cancer Res. Dec. 15. 2008;14(24):8244-52. Not eligible outcomes. [pmid: 19088042].
174 Ballesio L, Maggi C, Savelli S, et al. Role of breast magnetic resonance imaging (MRI) in patients with unilateral nipple discharge: preliminary study. Radiol Med (Torino). Mar. 2008;113(2):249-64. Not eligible outcomes. [pmid: 18386126].
175 Ballesio L, Maggi C, Savelli S, et al. Adjunctive diagnostic value of ultrasonography evaluation in patients with suspected ductal breast disease. Radiol Med (Torino). Apr. 2007;112(3):354-65. Not eligible outcomes. [pmid: 17440697].
176 Banerjee S, Dhar G, Haque I, et al. CCN5/WISP-2 expression in breast adenocarcinoma is associated with less frequent progression of the disease and suppresses the invasive phenotypes of tumor cells. Cancer Res. Sep. 15. 2008;68(18):7606-12. Not eligible outcomes. [pmid: 18794149].
177 Banerjee S, Smith IE, Folkerd L, et al. Comparative effects of anastrozole, tamoxifen alone and in combination on plasma lipids and bone-derived resorption during neoadjuvant therapy in the impact trial. Ann Oncol. Oct. 2005;16(10):1632-8. Not eligible target population. [pmid: 16030027].
178 Bankfalvi A, Ludwig A, De-Hesselle B, et al. Different proliferative activity of the glandular and myoepithelial lineages in benign proliferative and early malignant breast diseases. Mod Pathol. Sep. 2004;17(9):1051-61. Not eligible outcomes. [pmid: 15254552].
179 Bankhead A 3rd, Magnuson NS, Heckendorn RB. Cellular automaton simulation examining progenitor hierarchy structure effects on mammary ductal carcinoma in situ. J Theor Biol. Jun. 7. 2007;246(3):491-8. Secondary data analysis. [pmid: 17335852].
180 Baqai T, Shousha S. Oestrogen receptor negativity as a marker for high-grade ductal carcinoma in situ of the breast. Histopathology. May. 2003;42(5):440-7. Not eligible outcomes. [pmid: 12713620].
181 Barbacioru C, Arunachalam A, Cowden D, et al. Pharmacokinetic mapping of breast tumors: a new statistical analysis technique for dynamic magnetic resonance imaging. AMIA Annu Symp Proc. 2003;783. Not eligible outcomes.
182 Barnes N, Haywood P, Flint P, et al. Survivin expression in in situ and invasive breast cancer relates to COX-2 expression and DCIS recurrence. Br J Cancer. Jan. 30. 2006;94(2):253-8. Not eligible outcomes. [pmid: 16421596].
183 Barnes NL, Boland GP, Davenport A, et al. Relationship between hormone receptor status and tumour size, grade and comedo necrosis in ductal carcinoma in situ. Br J Surg. Apr. 2005;92(4):429-34. Not eligible outcomes. [pmid: 15736216].
184 Barnes PJ, Boutilier R, Chiasson D, et al. Metaplastic breast carcinoma: clinical-pathologic characteristics and HER2/neu expression. Breast Cancer Res Treat. May. 2005;91(2):173-8. Not eligible outcomes. [pmid: 15868445].
185 Barnes PJ, Dumont RJ, Higgins HG. Acinar pattern of mammary Paget’s disease: a case report. Breast J. Sep–Oct. 2007;13(5):520-6. Case Reports. [pmid: 17760678].
186 Barr R, Dann F. Anaplastic thyroid carcinoma metastatic to skin. J Cutan Pathol. 1974;1(5):201-6. Case Reports. [pmid: 4377844].
187 Barratt A, Howard K, Irwig L, et al. Model of outcomes of screening mammography: information to support informed choices. BMJ. Apr. 23. 2005;330(7497):936. Secondary data analysis. [pmid: 15755755].
188 Barreau B, de Mascarel I, Feuga C, et al. Mammography of ductal carcinoma in situ of the breast: review of 909 cases with radiographic-pathologic correlations. Eur J Radiol. Apr. 2005;54(1):55-61. Not eligible outcomes. [pmid: 15797293].
189 Barros A, Cardoso MA, Sheng PY, et al. Radioguided localisation of non-palpable breast lesions and simultaneous sentinel lymph node mapping. Eur J Nucl Med Mol Imaging. Dec. 2002;29(12):1561-5. Not eligible outcomes. [pmid: 12458388].
190 Barth PJ, Ebrahimsade S, Ramaswamy A, et al. CD34+ fibrocytes in invasive ductal carcinoma, ductal carcinoma in situ, and benign breast lesions. Virchows Arch. Mar. 2002;440(3):298-303. Not eligible outcomes. [pmid: 11889601].
191 Bartley AN, Ross DW. Validation of p53 immunohistochemistry as a prognostic factor in breast cancer in clinical practice. Arch Pathol Lab Med. Apr. 2002;126(4):456-8. Not eligible target population. [pmid: 11900572].
192 Bassett LW, Liu TH, Giuliano AE, et al. The prevalence of carcinoma in palpable vs impalpable, mammographically detected lesions. AJR Am J Roentgenol. Jul. 1991;157(1):21-4. Not eligible target population. [pmid: 1646562].
193 Basu CB, Wahba M, Bullocks JM, et al. Paget disease of a nipple graft following completion of a breast reconstruction with a nipple-sharing technique. Ann Plast Surg. Feb. 2008;60(2):144-5. Case Reports. [pmid: 18216504].
194 Basu SK, Schwartz C, Fisher SG, et al. Unilateral and bilateral breast cancer in women surviving pediatric Hodgkin’s disease. Int J Radiat Oncol Biol Phys. Sep. 1. 2008;72(1):34-40. Not eligible level of evidence. [pmid: 18722264].
195 Bates GJ, Fox SB, Han C, et al. Quantification of regulatory T cells enables the identification of high-risk breast cancer patients and those at risk of late relapse. J Clin Oncol. Dec. 1. 2006;24(34):5373-80. Not eligible level of evidence. [pmid: 17135638].
196 Battifora H. Intracytoplasmic lumina in breast carcinoma: a helpful histopathologic feature. Arch Pathol. Nov. 1975;99(11):614-7. Case Reports. [pmid: 179516].
197 Bauer RL, Eckhert KH Jr, Nemoto T. Ductal carcinoma in situ-associated nipple discharge: a clinical marker for locally extensive disease. Ann Surg Oncol. Jul–Aug. 1998;5(5):452-5. Not eligible level of evidence. [pmid: 9718176].
198 Bauer TL, Pandelidis SM, Rhoads JE Jr. Five-year survival of 100 women with carcinoma of the breast diagnosed by screening mammography and needle-localization biopsy. J Am Coll Surg. May. 1994;178(5):427-30. Not eligible level of evidence. [pmid: 8167877].
199 Bauer TW, Spitz FR, Callans LS, et al. Subareolar and peritumoral injection identify similar sentinel nodes for breast cancer. Ann Surg Oncol. Mar. 2002;9(2):169-76. Not eligible target population. [pmid: 11888875].
200 Bauer TW, Tubbs RR, Edinger MG, et al. A prospective comparison of DNA quantitation by image and flow cytometry. Am J Clin Pathol. Mar. 1990;93(3):322-6. Not eligible outcomes. [pmid: 2155525].
201 Bauer VP, Ditkoff BA, Schnabel F, et al. The management of lobular neoplasia identified on percutaneous core breast biopsy. Breast J. Jan–Feb. 2003;9(1):4-9. Not eligible outcomes. [pmid: 12558663].
202 Baum M, Budzar AU, Cuzick J, et al. Anastrozole alone or in combination with tamoxifen versus tamoxifen alone for adjuvant treatment of postmenopausal women with early breast cancer: first results of the ATAC randomised trial. Lancet. Jun. 22. 2002;359(9324):2131-9. Not eligible outcomes. [pmid: 12090977].
203 Beaber EF, Holt VL, Malone KE, et al. Reproductive factors, age at maximum height, and risk of three histologic types of breast cancer. Cancer Epidemiol Biomarkers Prev. Dec. 2008;17(12):3427-34. Not eligible target population. [pmid: 19064558].
204 Bean GR, Ibarra Drendall C, Goldenberg VK, et al. Hypermethylation of the breast cancer-associated gene 1 promoter does not predict cytologic atypia or correlate with surrogate end points of breast cancer risk. Cancer Epidemiol Biomarkers Prev. Jan. 2007;16(1):50-6. Not eligible outcomes. [pmid: 17220331].
205 Bean GR, Scott V, Yee L, et al. Retinoic acid receptor-beta2 promoter methylation in random periareolar fine needle aspiration. Cancer Epidemiol Biomarkers Prev. Apr. 2005;14(4):790-8. Not eligible outcomes. [pmid: 15824145].
206 Beck JS. Observer variability in reporting of breast lesions. J Clin Pathol. Dec. 1985;38(12):1358-65. Not eligible outcomes. [pmid: 3001153].
207 Becker H. Breast reconstruction using an inflatable breast implant with detachable reservoir. Plast Reconstr Surg. Apr. 1984;73(4):678-83. Not eligible target population. [pmid: 6709750].
208 Bedei L, Falcini F, Sanna PA, et al. Atypical ductal hyperplasia of the breast: the controversial management of a borderline lesion: experience of 47 cases diagnosed at vacuum-assisted biopsy. Breast. Apr. 2006;15(2):196-202. Not eligible outcomes. [pmid: 16055333].
209 Bedrosian I, Mick R, Orel SG, et al. Changes in the surgical management of patients with breast carcinoma based on preoperative magnetic resonance imaging. Cancer. Aug. 1. 2003;98(3):468-73. Not eligible target population. [pmid: 12879462].
210 Bedrosian I, Schlencker J, Spitz FR, et al. Magnetic resonance imaging-guided biopsy of mammographically and clinically occult breast lesions. Ann Surg Oncol. Jun. 2002;9(5):457-61. Not eligible outcomes. [pmid: 12052756].
211 Beerman H, Bonsing BA, van de Vijver MJ, et al. DNA ploidy of primary breast cancer and local recurrence after breast-conserving therapy. Br J Cancer. Jul. 1991;64(1):139-43. Not eligible outcomes. [pmid: 1854613].
212 Behrenbruch CP, Marias K, Armitage PA, et al. Fusion of contrast-enhanced breast MR and mammographic imaging data. Med Image Anal. Sep. 2003;7(3):311-40. Case Reports. [pmid: 12946471].
213 Bell CD, Stadler J, Michowitz M, et al. Relationship of nuclear appearance to stromal invasion in human breast cancer. J Surg Oncol. May. 1987;35(1):63-9. Not eligible outcomes. [pmid: 3033402].
214 Ben-Baruch G, Segal O, Serlin J, et al. Metastases to the endometrium from breast carcinoma. Eur J Gynaecol Oncol. 1990;11(1):61-6. Case Reports. [pmid: 2161338].
215 Bender CM, Sereika SM, Berga SL, et al. Cognitive impairment associated with adjuvant therapy in breast cancer. Psychooncology. May. 2006;15(5):422-30. Not eligible target population. [pmid: 16097037].
216 Benson SR, Blue J, Judd K, et al. Ultrasound is now better than mammography for the detection of invasive breast cancer. Am J Surg. Oct. 2004;188(4):381-5. Not eligible outcomes. [pmid: 15474430].
217 Bentley CR, Davies G, Aclimandos WA. Tamoxifen retinopathy: a rare but serious complication. BMJ. Feb. 22. 1992;304(6825):495-6. Case Reports. [pmid: 1312376].
218 Berg WA, Arnoldus CL, Teferra E, et al. Biopsy of amorphous breast calcifications: pathologic outcome and yield at stereotactic biopsy. Radiology. Nov. 2001;221(2):495-503. Not eligible outcomes. [pmid: 11687695].
219 Berg WA, Gilbreath PL. Multicentric and multifocal cancer: whole-breast US in preoperative evaluation. Radiology. Jan. 2000;214(1):59-66. Not eligible outcomes. [pmid: 10644102].
220 Berg WA, Gutierrez L, NessAiver MS, et al. Diagnostic accuracy of mammography, clinical examination, US, and MR imaging in preoperative assessment of breast cancer. Radiology. Dec. 2004;233(3):830-49. Not eligible level of evidence. [pmid: 15486214].
221 Berg WA, Mrose HE, Ioffe OB. Atypical lobular hyperplasia or lobular carcinoma in situ at core-needle breast biopsy. Radiology. Feb. 2001;218(2):503-9. Not eligible target population. [pmid: 11161169].
222 Berg WA, Weinberg IN, Narayanan D, et al. High-resolution fluorodeoxyglucose positron emission tomography with compression (“positron emission mammography”) is highly accurate in depicting primary breast cancer. Breast J. Jul–Aug. 2006;12(4):309-23. Not eligible outcomes. [pmid: 16848840].
223 Bergman S, Hoda SA, Geisinger KR, et al. E-cadherin-negative primary small cell carcinoma of the breast. Report of a case and review of the literature. Am J Clin Pathol. Jan. 2004;121(1):117-21. Not eligible outcomes. [pmid: 14750249].
224 Berman H, Zhang J, Crawford YG, et al. Genetic and epigenetic changes in mammary epithelial cells identify a subpopulation of cells involved in early carcinogenesis. Cold Spring Harb Symp Quant Biol. 2005;70:317-27. Not eligible outcomes. [pmid: 16869768].
225 Bernaerts A, De Schepper A Jr, Van Dam P, et al. Clip migration after vacuum-assisted stereotactic breast biopsy: a pitfall in preoperative wire localization. JBR-BTR. May–Jun. 2007;90(3):172-5. Case Reports. [pmid: 17696084].
226 Bernardi M, Brown AS, Malone JC, et al. Paget disease in a man. Arch Dermatol. Dec. 2008;144(12):1660-2. Not eligible target population. [pmid: 19075160].
227 Bernathova M, Zelger B, Deardon D, et al. Sonographic findings of an intraductal mucinous carcinoma. J Ultrasound Med. Jul. 2006;25(7):925-7. Case Reports. [pmid: 16798906].
228 Bernhard J, Castiglione-Gertsch M, Schmitz SF, et al. Quality of life in postmenopausal patients with breast cancer after failure of tamoxifen: formestane versus megestrol acetate as second-line hormonal treatment. Swiss Group for Clinical Cancer Research (SAKK). Eur J Cancer. Jun. 1999;35(6):913-20. Not eligible target population. [pmid: 10533471].
229 Bernhard J, Thurlimann B, Schmitz SF, et al. Defining clinical benefit in postmenopausal patients with breast cancer under second-line endocrine treatment: does quality of life matter. J Clin Oncol. Jun. 1999;17(6):1672-9. Not eligible target population. [pmid: 10561203].
230 Bernhardt G, Reile H, Birnbock H, et al. Standardized kinetic microassay to quantify differential chemosensitivity on the basis of proliferative activity. J Cancer Res Clin Oncol. 1992;118(1):35-43. Not eligible outcomes. [pmid: 1309532].
231 Berois N, Mazal D, Ubillos L, et al. UDP-N-acetyl-D-galactosamine: polypeptide N-acetylgalactosaminyltransferase-6 as a new immunohistochemical breast cancer marker. J Histochem Cytochem. Mar. 2006;54(3):317-28. Not eligible outcomes. [pmid: 16260590].
232 Bertheau P, Steinberg SM, Cowan K, et al. Breast cancer in young women: clinicopathologic correlation. Semin Diagn Pathol. Aug. 1999;16(3):248-56. Not eligible outcomes. [pmid: 10490201].
233 Bertolo C, Guerrero D, Vicente F, et al. Differences and molecular immunohistochemical parameters in the subtypes of infiltrating ductal breast cancer. Am J Clin Pathol. Sep. 2008;130(3):414-24. Not eligible target population. [pmid: 18701415].
234 Besic N, Zgajnar J, Hocevar M, et al. Breast biopsy with wire localization: factors influencing complete excision of nonpalpable carcinoma. Eur Radiol. Nov. 2002;12(11):2684-9. Not eligible outcomes. [pmid: 12386758].
235 Bessell-Browne R, Beer T, Wylie E. Tungsten particles mimicking the microcalcifications seen in ductal carcinoma in situ. Australas Radiol. Feb. 2006;50(1):87-90. Case Reports. [pmid: 16499738].
236 Betsill WL Jr, Rosen PP, Lieberman PH, et al. Intraductal carcinoma. Long-term follow-up after treatment by biopsy alone. JAMA. May. 5. 1978;239(18):1863-7. Not eligible level of evidence. [pmid: 205686].
237 Bettini AC, Tondini C, Poletti P, et al. A case of interstitial pneumonitis associated with Guillain-Barre syndrome during administration of adjuvant trastuzumab. Tumori. Sep–Oct. 2008;94(5):737-41. Case Reports. [pmid: 19112950].
238 Beute BJ, Kalisher L, Hutter RV. Lobular carcinoma in situ of the breast: clinical, pathologic, and mammographic features. AJR Am J Roentgenol. Aug. 1991;157(2):257-65. Not eligible outcomes. [pmid: 1853802].
239 Bhadani PP, Sharma MC, Sah SP, et al. Paget’s disease of the nipple diagnosed on cytology: a case report. Indian J Pathol Microbiol. Apr. 2004;47(2):246-8. Not eligible target population. [pmid: 16295486].
240 Bianco MK, Vasef MA. HER-2 gene amplification in Paget disease of the nipple and extramammary site: a chromogenic in situ hybridization study. Diagn Mol Pathol. Sep. 2006;15(3):131-5. Not eligible target population. [pmid: 16932067].
241 Bibbo M, Scheiber M, Cajulis R, et al. Stereotaxic fine needle aspiration cytology of clinically occult malignant and premalignant breast lesions. Acta Cytol. Mar–Apr. 1988;32(2):193-201. Not eligible outcomes. [pmid: 2831687].
242 Biesterfeld S, Kusche M, Viereck E, et al. Limited value of the NKI/C3-antibody for the differential diagnosis of Paget’s disease of the nipple and intra-epidermal malignant melanoma. Histopathology. Mar. 1996;28(3):269-70. Not eligible target population. [pmid: 8729049].
243 Bigenwald RZ, Warner E, Gunasekara A, et al. Is mammography adequate for screening women with inherited BRCA mutations and low breast density. Cancer Epidemiol Biomarkers Prev. Mar. 2008;17(3):706-11. Not eligible outcomes. [pmid: 18349291].
244 Bijker N, Peterse JL, Duchateau L, et al. Histological type and marker expression of the primary tumour compared with its local recurrence after breast-conserving therapy for ductal carcinoma in situ. Br J Cancer. Feb. 2001;84(4):539-44. No associative hypothesis tested. [pmid: 11207051].
245 Bijker N, Peterse JL, Fentiman IS, et al. Effects of patient selection on the applicability of results from a randomised clinical trial (EORTC 10853) investigating breast-conserving therapy for DCIS. Br J Cancer. Sep. 9. 2002;87(6):615-20. No associative hypothesis tested. [pmid: 12237770].
246 Bijker N, Rutgers EJ, Duchateau L, et al. Breast-conserving therapy for Paget disease of the nipple: a prospective European Organization for Research and Treatment of Cancer study of 61 patients. Cancer. Feb. 1. 2001;91(3):472-7. Not eligible target population. [pmid: 11169928].
247 Bijker N, Rutgers EJ, Peterse JL, et al. Variations in diagnostic and therapeutic procedures in a multicentre, randomized clinical trial (EORTC 10853) investigating breast-conserving treatment for DCIS. Eur J Surg Oncol. Mar. 2001;27(2):135-40. Not eligible outcomes. [pmid: 11289747].
248 Bilimoria KY, Cambic A, Hansen NM, et al. Evaluating the impact of preoperative breast magnetic resonance imaging on the surgical management of newly diagnosed breast cancers. Arch Surg. May. 2007;142(5):441-5. discussion 5-7. Not eligible outcomes. [pmid: 17515485].
249 Bingham HG, Copeland EM, Hackett R, et al. Breast cancer in a patient with silicone breast implants after 13 years. Ann Plast Surg. Mar. 1988;20(3):236-7. Case Reports. [pmid: 2833868].
250 Biran S, Keren A, Farkas T, et al. Development of carcinoma of the breast at the site of an implanted pacemaker in two patients. J Surg Oncol. 1979;11(1):7-11. Not eligible target population. [pmid: 219300].
251 Bircan S, Kapucuoglu N, Baspinar S, et al. CD24 expression in ductal carcinoma in situ and invasive ductal carcinoma of breast: an immunohistochemistry-based pilot study. Pathol Res Pract. 2006;202(8):569-76. Not eligible outcomes. [pmid: 16828238].
252 Birnbaum L. Use of dermal grafts to cover implants in breast reconstructions. Plast Reconstr Surg. Apr. 1979;63(4):487-91. Case Reports. [pmid: 218239].
253 Birsner JW, Gershon-Cohen J. Diagnostic scoring system for mammary carcinoma. Acta Radiol Ther Phys Biol. Oct. 1973;12(5):387-96. Not eligible outcomes. [pmid: 4360141].
254 Bishop CC, Singh S, Nash AG. Mastectomy and breast reconstruction preserving the nipple. Ann R Coll Surg Engl. Mar. 1990;72(2):87-9. Not eligible target population. [pmid: 2159252].
255 Blackwell K, Haroon Z, Broadwater G, et al. Plasma D-dimer levels in operable breast cancer patients correlate with clinical stage and axillary lymph node status. J Clin Oncol. Feb. 2000;18(3):600-8. Not eligible outcomes. [pmid: 10653875].
256 Blamey RW. Guidelines on endocrine therapy of breast cancer EUSOMA. Eur J Cancer. Mar. 2002;38(5):615-34. Guidelines. [pmid: 11916542].
257 Blanchard DK, Donohue JH, Reynolds C, et al. Relapse and morbidity in patients undergoing sentinel lymph node biopsy alone or with axillary dissection for breast cancer. Arch Surg. May. 2003;138(5):482-7. discussion 7-8. Not eligible target population. [pmid: 12742949].
258 Bleicher RJ, Abrahamse P, Hawley ST, et al. The influence of age on the breast surgery decision-making process. Ann Surg Oncol. Mar. 2008;15(3):854-62. Not eligible exposure. [pmid: 18058182].
259 Bluemke DA, Fishman EK, Kuhlman J. CT evaluation following Whipple procedure: potential pitfalls in interpretation. J Comput Assist Tomogr. Sep–Oct. 1992;16(5):704-8. Not eligible target population. [pmid: 1355779].
260 Blum KA, Johnson JL, Niedzwiecki D, et al. Prolonged follow-up after initial therapy with 2-chlorodeoxyadenosine in patients with indolent non-Hodgkin lymphoma: results of Cancer and Leukemia Group B Study 9153. Cancer. Dec. 15. 2006;107(12):2817-25. Not eligible level of evidence. [pmid: 17120198].
261 Bluman LG, Borstelmann NA, Rimer BK, et al. Knowledge, satisfaction, and perceived cancer risk among women diagnosed with ductal carcinoma in situ. J Womens Health Gend Based Med. Jul–Aug. 2001;10(6):589-98. Not eligible outcomes. [pmid: 11559456].
262 Blumenthal NC, Sood UR, Aronson PJ, et al. Facial ulcerations in an immunocompromised patient. Ecthyma gangrenosum. Arch Dermatol. Apr. 1990;126(4):529. 32. Case Reports. [pmid: 2157373].
263 Boccardo F. Switching to anastrozole after tamoxifen improves survival in postmenopausal women with breast cancer. Nat Clin Pract Oncol. Feb. 2008;5(2):76-7. Not eligible target population. [pmid: 17998944].
264 Boccardo F, Rubagotti A, Aldrighetti D, et al. Switching to an aromatase inhibitor provides mortality benefit in early breast carcinoma: pooled analysis of 2 consecutive trials. Cancer. Mar. 15. 2007;109(6):1060-7. Not eligible target population. [pmid: 17295293].
265 Boccardo F, Rubagotti A, Amoroso D, et al. Sequential tamoxifen and aminoglutethimide versus tamoxifen alone in the adjuvant treatment of postmenopausal breast cancer patients: results of an Italian cooperative study. J Clin Oncol. Nov. 15. 2001;19(22):4209-15. Not eligible target population. [pmid: 11709564].
266 Boccardo F, Rubagotti A, Puntoni M, et al. Switching to anastrozole versus continued tamoxifen treatment of early breast cancer: preliminary results of the Italian Tamoxifen Anastrozole Trial. J Clin Oncol. Aug. 1. 2005;23(22):5138-47. Not eligible target population. [pmid: 16009955].
267 Bocker W, Hungermann D, Weigel S, et al. Atypical ductal hyperplasia and atypical epithelial proliferation of ductal type. Pathologe. 2009. Jan. 22. Language.
268 Bocker W, Moll R, Poremba C, et al. Common adult stem cells in the human breast give rise to glandular and myoepithelial cell lineages: a new cell biological concept. Lab Invest. Jun. 2002;82(6):737-46. Not eligible outcomes. [pmid: 12065684].
269 Bocklage T, Lee KR, Belinson JL. Uterine mullerian adenosarcoma following adenomyoma in a woman on tamoxifen therapy. Gynecol Oncol. Jan. 1992;44(1):104-9. Case Reports. [pmid: 1309716].
270 Bodey B, Siegel SE, Kaiser HE. Restoration of the thymic cellular microenvironment following autologous bone marrow transplantation. In Vivo. Mar–Apr. 2002;16(2):127-40. Not eligible outcomes. [pmid: 12073772].
271 Bodian CA, Perzin KH, Lattes R. Lobular neoplasia. Long term risk of breast cancer and relation to other factors. Cancer. Sep. 1. 1996;78(5):1024-34. Not eligible target population. [pmid: 8780540].
272 Bodian CA, Perzin KH, Lattes R, et al. Prognostic significance of benign proliferative breast disease. Cancer. Jun. 15. 1993;71(12):3896-907. Not eligible outcomes. [pmid: 8389654].
273 Boecker W, Buerger H, Schmitz K, et al. Ductal epithelial proliferations of the breast: a biological continuum? Comparative genomic hybridization and high-molecular-weight cytokeratin expression patterns. J Pathol. Nov. 2001;195(4):415-21. Not eligible outcomes. [pmid: 11745672].
274 Boetes C, Mann RM. Ductal carcinoma in situ and breast MRI. Lancet. Aug. 11. 2007;370(9586):459-60. Comment. [pmid: 17693157].
275 Boetes C, Strijk SP, Holland R, et al. False-negative MR imaging of malignant breast tumors. Eur Radiol. 1997;7(8):1231-4. Not eligible level of evidence. [pmid: 9377507].
276 Bofin AM, Qvigstad G, Waldum C, et al. Neuroendocrine differentiation in carcinoma of the breast. Tyramide signal amplification discloses chromogranin A-positive tumour cells in more breast tumours than previously realized. APMIS. Sep. 2002;110(9):658-64. Not eligible outcomes. [pmid: 12529020].
277 Boland GP, Butt IS, Prasad R, et al. COX-2 expression is associated with an aggressive phenotype in ductal carcinoma in situ. Br J Cancer. Jan. 26. 2004;90(2):423-9. Not eligible outcomes. [pmid: 14735188].
278 Boland GP, McKeown A, Chan KC, et al. Biological response to hormonal manipulation in oestrogen receptor positive ductal carcinoma in situ of the breast. Br J Cancer. Jul. 21. 2003;89(2):277-83. Not eligible outcomes. [pmid: 12865917].
279 Bonadona V, Dussart-Moser S, Voirin N, et al. Prognosis of early-onset breast cancer based on BRCA1/2 mutation status in a French population-based cohort and review. Breast Cancer Res Treat. Jan. 2007;101(2):233-45. Not eligible target population. [pmid: 17061047].
280 Bondeson L, Linell F, Ringberg A. Breast reductions: what to do with all the tissue specimens. Histopathology. Mar. 1985;9(3):281-5. Not eligible outcomes. [pmid: 3997085].
281 Bone B, Aspelin P, Isberg B, et al. Contrast-enhanced MR imaging of the breast in patients with breast implants after cancer surgery. Acta Radiol. Mar. 1995;36(2):111-6. Not eligible outcomes. [pmid: 7710787].
282 Bonett A, Dorsch M, Roder D, et al. Infiltrating ductal carcinoma of the breast in South Australia. Implications of trends in tumour diameter, nodal status and case-survival rates for cancer control. Med J Aust. Jan. 1. 1990;152(1):19-23. Not eligible target population. [pmid: 2152955].
283 Bonett A, Roder D, Esterman A. Case-survival rates for infiltrating ductal carcinomas by category of hospital at diagnosis in South Australia. Med J Aust. May. 20. 1991;154(10):695-7. Not eligible outcomes. [pmid: 1851945].
284 Bonneterre J, Buzdar A, Nabholtz JM, et al. Anastrozole is superior to tamoxifen as first-line therapy in hormone receptor positive advanced breast carcinoma. Cancer. Nov. 1. 2001;92(9):2247-58. Not eligible target population. [pmid: 11745278].
285 Bonneterre J, Coppens H, Mauriac L, et al. Aminoglutethimide in advanced breast cancer: clinical results of a French multicenter randomized trial comparing 500 mg and 1 g/day. Eur J Cancer Clin Oncol. Oct. 1985;21(10):1153-8. Not eligible target population. [pmid: 3908116].
286 Bonneterre J, Thurlimann B, Robertson JF, et al. Anastrozole versus tamoxifen as first-line therapy for advanced breast cancer in 668 postmenopausal women: results of the Tamoxifen or Arimidex Randomized Group Efficacy and Tolerability study. J Clin Oncol. Nov. 15. 2000;18(22):3748-57. Not eligible target population. [pmid: 11078487].
287 Bonnett M, Wallis T, Rossmann M, et al. Histologic and radiographic analysis of ductal carcinoma in situ diagnosed using stereotactic incisional core breast biopsy. Mod Pathol. Feb. 2002;15(2):95-101. Not eligible outcomes. [pmid: 11850537].
288 Bonzanini M, Gilioli E, Brancato B, et al. The cytopathology of ductal carcinoma in situ of the breast. A detailed analysis of fine needle aspiration cytology of 58 cases compared with 101 invasive ductal carcinomas. Cytopathology. Apr. 2001;12(2):107-19. Not eligible outcomes. [pmid: 11284955].
289 Boonjunwetwatmd D, Chyutipraiwan U, Sampatanukul P, et al. Sensitivity of mammography and ultrasonography on detecting abnormal findings of ductal carcinoma in situ. J Med Assoc Thai. Mar. 2007;90(3):539-45. Not eligible outcomes. [pmid: 17427533].
290 Bordeleau L, Rakovitch E, Naimark DM, et al. A comparison of four treatment strategies for ductal carcinoma in situ using decision analysis. Cancer. Jul. 1. 2001;92(1):23-9. No primary data. [pmid: 11443605].
291 Borgmann K, Hoeller U, Nowack S, et al. Individual radiosensitivity measured with lymphocytes may predict the risk of acute reaction after radiotherapy. Int J Radiat Oncol Biol Phys. May. 1. 2008;71(1):256-64. Not eligible target population. [pmid: 18406889].
292 Bornstein BA, Recht A, Connolly JL, et al. Results of treating ductal carcinoma in situ of the breast with conservative surgery and radiation therapy. Cancer. Jan. 1. 1991;67(1):7-13. Not eligible level of evidence. [pmid: 1845938].
293 Bosset JF, Pavy JJ, Gillet M, et al. Conventional external irradiation alone as adjuvant treatment in resectable pancreatic cancer: results of a prospective study. Radiother Oncol. Jul. 1992;24(3):191-4. Not eligible target population. [pmid: 1357725].
294 Bostwick J 3rd, Paletta C, Hartrampf CR. Conservative treatment for breast cancer. Complications requiring reconstructive surgery. Ann Surg. May. 1986;203(5):481-90. Case Reports. [pmid: 3010888].
295 Bottini A, Generali D, Brizzi MP, et al. Randomized phase II trial of letrozole and letrozole plus low-dose metronomic oral cyclophosphamide as primary systemic treatment in elderly breast cancer patients. J Clin Oncol. Aug. 1. 2006;24(22):3623-8. Not eligible target population. [pmid: 16877730].
296 Boulos FI, Dupont WD, Simpson JF, et al. Histologic associations and long-term cancer risk in columnar cell lesions of the breast: a retrospective cohort and a nested case-control study. Cancer. Nov. 1. 2008;113(9):2415-21. Not eligible outcomes. [pmid: 18816618].
297 Boulware RJ, Byars L, Neglia WJ, et al. Treatment of early breast cancer with limited surgery and radiation therapy. J S C Med Assoc. Dec. 1992;88(12):566-9. Not eligible target population. [pmid: 1336801].
298 Boute V, Goyat I, Denoux Y, et al. Are the criteria of Tabar and Dean still relevant to radial scar. Eur J Radiol. Nov. 2006;60(2):243-9. Not eligible outcomes. [pmid: 16962279].
299 Bover L, Barrio M, Slavutsky I, et al. Description of a new human breast cancer cell line, IIB-BR-G, established from a primary undifferentiated tumor. Breast Cancer Res Treat. Sep. 1991;19(1):47-56. Not eligible target population. [pmid: 1661624].
300 Boyages J, Recht A, Connolly JL, et al. Early breast cancer: predictors of breast recurrence for patients treated with conservative surgery and radiation therapy. Radiother Oncol. Sep. 1990;19(1):29-41. Not eligible target population. [pmid: 2173044].
301 Boyd DB. Integrative tumor board: recurrent breast cancer or new primary? Medical oncology. Integr Cancer Ther. Sep. 2003;2(3):270-2. Case Reports. [pmid: 15035890].
302 Boyd NF, Rommens JM, Vogt K, et al. Mammographic breast density as an intermediate phenotype for breast cancer. Lancet Oncology. 2005;6(10):798-808. Review. [pmid: 16198986].
303 Bradbury JM, Arno J, Edwards PA. Induction of epithelial abnormalities that resemble human breast lesions by the expression of the neu/erbB-2 oncogene in reconstituted mouse mammary gland. Oncogene. Jun. 1993;8(6):1551-8. Not eligible target population. [pmid: 8099220].
304 Bradley SJ, Weaver DW, Bouwman DL. Alternatives in the surgical management of in situ breast cancer. A meta-analysis of outcome. Am Surg. Jul. 1990;56(7):428-32. Secondary data analysis. [pmid: 2164336].
305 Brady B, Fant J, Jones R, et al. Sentinel lymph node biopsy followed by delayed mastectomy and reconstruction. Am J Surg. Feb. 2003;185(2):114-7. Not eligible target population. [pmid: 12559439].
306 Brancato B, Houssami N, Francesca D, et al. Does computer-aided detection (CAD) contribute to the performance of digital mammography in a self-referred population?. Breast Cancer Research & Treatment. Sep. 2008;111(2):373-6. Not eligible outcomes. [pmid: 17939035].
307 Brandwein MS, Jagirdar J, Patil J, et al. Salivary duct carcinoma (cribriform salivary carcinoma of excretory ducts). A clinicopathologic and immunohistochemical study of 12 cases. Cancer. May. 15. 1990;65(10):2307-14. Not eligible target population. [pmid: 1693309].
308 Brandwein-Gensler M, Hille J, Wang BY, et al. Low-grade salivary duct carcinoma: description of 16 cases. Am J Surg Pathol. Aug. 2004;28(8):1040-4. Case Reports. [pmid: 15252310].
309 Bratthauer GL, Moinfar F, Stamatakos MD, et al. Combined E-cadherin and high molecular weight cytokeratin immunoprofile differentiates lobular, ductal, and hybrid mammary intraepithelial neoplasias. Hum Pathol. Jun. 2002;33(6):620-7. Not eligible outcomes. [pmid: 12152161].
310 Bratthauer GL, Saenger JS, Strauss BL. Antibodies targeting p63 react specifically in the cytoplasm of breast epithelial cells exhibiting secretory differentiation. Histopathology. Dec. 2005;47(6):611-6. Not eligible outcomes. [pmid: 16324199].
311 Bratthauer GL, Tavassoli FA. Lobular intraepithelial neoplasia: previously unexplored aspects assessed in 775 cases and their clinical implications. Virchows Arch. Feb. 2002;440(2):134-8. Not eligible level of evidence. [pmid: 11964042].
312 Bratthauer GL, Tavassoli FA. Assessment of lesions coexisting with various grades of ductal intraepithelial neoplasia of the breast. Virchows Arch. Apr. 2004;444(4):340-4. Not eligible outcomes. [pmid: 14986131].
313 Brem RF, Behrndt VS, Sanow L, et al. Atypical ductal hyperplasia: histologic underestimation of carcinoma in tissue harvested from impalpable breast lesions using 11-gauge stereotactically guided directional vacuum-assisted biopsy. AJR Am J Roentgenol. May. 1999;172(5):1405-7. Not eligible outcomes. [pmid: 10227526].
314 Brem RF, Floerke AC, Rapelyea JA, et al. Breast-specific gamma imaging as an adjunct imaging modality for the diagnosis of breast cancer. Radiology. Jun. 2008;247(3):651-7. Not eligible outcomes. [pmid: 18487533].
315 Brem RF, Lechner MC, Jackman RJ, et al. Lobular neoplasia at percutaneous breast biopsy: variables associated with carcinoma at surgical excision. AJR Am J Roentgenol. Mar. 2008;190(3):637-41. Not eligible outcomes. [pmid: 18287433].
316 Brem RF, Rapelyea JA, Zisman G, et al. Evaluation of breast cancer with a computer-aided detection system by mammographic appearance and histopathology. Cancer. Sep. 1. 2005;104(5):931-5. Not eligible outcomes. [pmid: 16047331].
317 Brem RF, Schoonjans JM, Goodman SN, et al. Nonpalpable breast cancer: percutaneous diagnosis with 11- and 8-gauge stereotactic vacuum-assisted biopsy devices. Radiology. Jun. 2001;219(3):793-6. Not eligible outcomes. [pmid: 11376271].
318 Brem RF, Schoonjans JM, Sanow L, et al. Reliability of histologic diagnosis of breast cancer with stereotactic vacuum-assisted biopsy. Am Surg. Apr. 2001;67(4):388-92. Not eligible outcomes. [pmid: 11308011].
319 Bremner AK, Recabaren J. The efficacy of MRI as an adjuvant to traditional mammography. Am Surg. Oct. 2007;73(10):970-2. Not eligible target population. [pmid: 17983059].
320 Brenner RJ. Lesions entirely removed during stereotactic biopsy: preoperative localization on the basis of mammographic landmarks and feasibility of freehand technique--initial experience. Radiology. Feb. 2000;214(2):585-90. Not eligible outcomes. [pmid: 10671616].
321 Brewster AM, Christo DK, Lai H, et al. Breast carcinoma chemoprevention in the community setting. Estimating risks and benefits. Cancer. Mar. 15. 2005;103(6):1147-53. Not eligible target population. [pmid: 15674856].
322 Brinton LA, Sherman ME, Carreon JD, et al. Recent trends in breast cancer among younger women in the United States. J Natl Cancer Inst. Nov. 19. 2008;100(22):1643-8. Not eligible outcomes. [pmid: 19001605].
323 Brittenden J, Watmough D, Heys SD, et al. Preliminary clinical evaluation of a combined optical Doppler ultrasound instrument for the detection of breast cancer. Br J Radiol. Dec. 1995;68(816):1344-8. Not eligible outcomes. [pmid: 8777596].
324 Britton PD. Picture Quiz Breast imaging. BMJ. 2008;337:a1313. Case Reports. [pmid: 18799535].
325 Britton PD, Coulden RA. The use of duplex Doppler ultrasound in the diagnosis of breast cancer. Clin Radiol. Dec. 1990;42(6):399-401. Not eligible outcomes. [pmid: 2175686].
326 Broekhuizen LN, Wijsman JH, Peterse JL, et al. The incidence and significance of micrometastases in lymph nodes of patients with ductal carcinoma in situ and T1a carcinoma of the breast. Eur J Surg Oncol. Jun. 2006;32(5):502-6. Not eligible level of evidence. [pmid: 16569492].
327 Brogi E, Robson M, Panageas KS, et al. Ductal lavage in patients undergoing mastectomy for mammary carcinoma: a correlative study. Cancer. Nov. 15. 2003;98(10):2170-6. Not eligible outcomes. [pmid: 14601086].
328 Brookland RK, Blumberg AL. Definitive irradiation following breast-conserving surgery for early stage breast cancer. Md Med J. Oct. 1990;39(10):959-62. Not eligible target population. [pmid: 2172689].
329 Brooks P, Malic C, Austen O. Intercostobrachial nerve injury from axillary dissection resulting in necrotizing fasciitis after a burn injury. Breast J. Jul–Aug. 2008;14(4):385-7. Case Reports. [pmid: 18687072].
330 Brooks PG, Gart S, Heldfond AJ, et al. Breast screening in the primary care office. A plea for early detection. J Reprod Med. Nov. 1982;27(11):685-9. Not eligible target population. [pmid: 6296384].
331 Brown LF, Guidi AJ, Schnitt SJ, et al. Vascular stroma formation in carcinoma in situ, invasive carcinoma, and metastatic carcinoma of the breast. Clin Cancer Res. May. 1999;5(5):1041-56. Not eligible outcomes. [pmid: 10353737].
332 Brown PW, Silverman J, Owens E, et al. Intraductal “noninfiltrating” carcinoma of the breast. Arch Surg. Oct. 1976;111(10):1063-7. Not eligible level of evidence. [pmid: 184756].
333 Bruetman D, Bloom K, Bines S. Ductal carcinoma in situ of the breast. Med Pediatr Oncol. 1989;17(3):227-31. Case Reports. [pmid: 2546028].
334 Brufsky A, Harker WG, Beck JT, et al. Zoledronic acid inhibits adjuvant letrozole-induced bone loss in postmenopausal women with early breast cancer. J Clin Oncol. Mar. 1. 2007;25(7):829-36. Not eligible target population. [pmid: 17159193].
335 Brummer O, Athar S, Riethdorf L, et al. Matrix-metalloproteinases 1, 2, and 3 and their tissue inhibitors 1 and 2 in benign and malignant breast lesions: an in situ hybridization study. Virchows Arch. Dec. 1999;435(6):566-73. Not eligible outcomes. [pmid: 10628798].
336 Brunhuber T, Haybaeck J, Schafer G, et al. Immunohistochemical tracking of an immune response in mammary Paget’s disease. Cancer Lett. Dec. 18. 2008;272(2):206-20. Not eligible outcomes. [pmid: 18842336].
337 Bruning PF, Bonfrer JM, Hart AA, et al. Low dose aminoglutethimide without hydrocortisone for the treatment of advanced postmenopausal breast cancer. Eur J Cancer Clin Oncol. Feb. 1989;25(2):369-76. Not eligible target population. [pmid: 2702989].
338 Bryan BB, Schnitt SJ, Collins LC. Ductal carcinoma in situ with basal-like phenotype: a possible precursor to invasive basal-like breast cancer. Mod Pathol. May. 2006;19(5):617-21. Not eligible outcomes. [pmid: 16528377].
339 Buchanan CL, Flynn LW, Murray MP, et al. Is pleomorphic lobular carcinoma really a distinct clinical entity. J Surg Oncol. Oct. 1. 2008;98(5):314-7. Not eligible target population. [pmid: 18668643].
340 Buchanan CL, Morris EA, Dorn PL, et al. Utility of breast magnetic resonance imaging in patients with occult primary breast cancer. Ann Surg Oncol. Dec. 2005;12(12):1045-53. Not eligible target population. [pmid: 16244803].
341 Buchholz TA. Radiation therapy for early-stage breast cancer after breast-conserving surgery. N Engl J Med. Jan. 1. 2009;360(1):63-70. Review. [pmid: 19118305].
342 Buchholz TA, Theriault RL, Niland JC, et al. The use of radiation as a component of breast conservation therapy in National Comprehensive Cancer Network Centers. J Clin Oncol. Jan. 20. 2006;24(3):361-9. Not eligible outcomes. [pmid: 16421417].
343 Buchler M, Friess H, Schultheiss KH, et al. A randomized controlled trial of adjuvant immunotherapy (murine monoclonal antibody 494/32) in resectable pancreatic cancer. Cancer. Oct. 1. 1991;68(7):1507-12. Not eligible target population. [pmid: 1654194].
344 Bulens P, Vanuytsel L, Rijnders A, et al. Breast conserving treatment of Paget’s disease. Radiother Oncol. Apr. 1990;17(4):305-9. Not eligible target population. [pmid: 2160679].
345 Bullerdiek J, Leuschner E, Taquia E, et al. Trisomy 8 as a recurrent clonal abnormality in breast cancer. Cancer Genet Cytogenet. Jan. 1993;65(1):64-7. Not eligible target population. [pmid: 8381713].
346 Bundred NJ, Campbell ID, Davidson N, et al. Effective inhibition of aromatase inhibitor-associated bone loss by zoledronic acid in postmenopausal women with early breast cancer receiving adjuvant letrozole: ZO-FAST Study results. Cancer. Mar. 1. 2008;112(5):1001-10. Not eligible target population. [pmid: 18205185].
347 Burbank F. Stereotactic breast biopsy of atypical ductal hyperplasia and ductal carcinoma in situ lesions: improved accuracy with directional, vacuum-assisted biopsy. Radiology. Mar. 1997;202(3):843-7. Not eligible outcomes. [pmid: 9051043].
348 Burke MF, Allison R, Tripcony L. Conservative therapy of breast cancer in Queensland. Int J Radiat Oncol Biol Phys. Jan. 15. 1995;31(2):295-303. Not eligible target population. [pmid: 7836083].
349 Burkholder HC, Witherspoon LE, Burns RP, et al. Breast surgery techniques: preoperative bracketing wire localization by surgeons. Am Surg. Jun. 2007;73(6):574-8. discussion 8-9. Not eligible target population. [pmid: 17658094].
350 Burki N, Buser M, Emmons LR, et al. Malignancies in families of women with medullary, tubular and invasive ductal breast cancer. Eur J Cancer. Mar. 1990;26(3):295-303. Not eligible target population. [pmid: 2162689].
351 Burnand KG, Bulman AS, Nash AG. The place of subcutaneous mastectomy with immediate silicone prosthetic implantation in diseases of the breast. Ann R Coll Surg Engl. Nov. 1980;62(6):449-53. Not eligible outcomes. [pmid: 7436304].
352 Burns RP, Brown JP, Roe SM, et al. Stereotactic core-needle breast biopsy by surgeons: minimum 2-year follow-up of benign lesions. Ann Surg. Oct. 2000;232(4):542-8. Not eligible outcomes. [pmid: 10998652].
353 Burri SH, Landry JC, Davis LW. Breast conservation is an effective option in Black, medically indigent patients. J Natl Med Assoc. Jun. 2002;94(6):453-8. Not eligible level of evidence. [pmid: 12078926].
354 Burton S, Li WY, Himpson R, et al. Microdochectomy in women aged over 50 years. Ann R Coll Surg Engl. Jan. 2003;85(1):47-9. Not eligible target population. [pmid: 12585633].
355 Bussolati G, Botto Micca FB, Eusebi V, et al. Myoepithelial cells in lobular carcinoma in situ of the breast: a parallel immunocytochemical and ultrastructural study. Ultrastruct Pathol. Jul–Sep. 1981;2(3):219-30. Not eligible target population. [pmid: 7197410].
356 Busund LT, Richardsen E, Busund R, et al. Significant expression of IGFBP2 in breast cancer compared with benign lesions. J Clin Pathol. Apr. 2005;58(4):361-6. Not eligible outcomes. [pmid: 15790698].
357 Butta A, MacLennan K, Flanders KC, et al. Induction of transforming growth factor beta 1 in human breast cancer in vivo following tamoxifen treatment. Cancer Res. Aug. 1. 1992;52(15):4261-4. Not eligible outcomes. [pmid: 1322240].
358 Buzdar A, Douma J, Davidson N, et al. Phase III, multicenter, double-blind, randomized study of letrozole, an aromatase inhibitor, for advanced breast cancer versus megestrol acetate. J Clin Oncol. Jul. 15. 2001;19(14):3357-66. Not eligible target population. [pmid: 11454883].
359 Buzdar A, Howell A, Cuzick J, et al. Comprehensive side-effect profile of anastrozole and tamoxifen as adjuvant treatment for early-stage breast cancer: long-term safety analysis of the ATAC trial. Lancet Oncol. Aug. 2006;7(8):633-43. Not eligible target population. [pmid: 16887480].
360 Buzdar A, Jonat W, Howell A, et al. Anastrozole, a potent and selective aromatase inhibitor, versus megestrol acetate in postmenopausal women with advanced breast cancer: results of overview analysis of two phase III trials. Arimidex Study Group. J Clin Oncol. Jul. 1996;14(7):2000-11. Not eligible target population. [pmid: 8683230].
361 Buzdar AU, Cuzick J. Anastrozole as an adjuvant endocrine treatment for postmenopausal patients with breast cancer: emerging data. Clin Cancer Res. Feb. 3 Pt 2. 2006;1(12):1037s-48s. Not eligible target population. [pmid: 16467122].
362 Buzdar AU, Jonat W, Howell A, et al. Anastrozole versus megestrol acetate in the treatment of postmenopausal women with advanced breast carcinoma: results of a survival update based on a combined analysis of data from two mature phase III trials. Arimidex Study Group. Cancer. Sep. 15. 1998;83(6):1142-52. Not eligible target population. [pmid: 9740079].
363 Buzdar AU, Jones SE, Vogel CL, et al. A phase III trial comparing anastrozole (1 and 10 milligrams), a potent and selective aromatase inhibitor, with megestrol acetate in postmenopausal women with advanced breast carcinoma. Arimidex Study Group. Cancer. Feb. 15. 1997;79(4):730-9. Not eligible target population. [pmid: 9024711].
364 Cabioglu N, Hunt KK, Sahin AA, et al. Role for intraoperative margin assessment in patients undergoing breast-conserving surgery. Ann Surg Oncol. Apr. 2007;14(4):1458-71. Not eligible outcomes. [pmid: 17260108].
365 Cabioglu N, Krishnamurthy S, Kuerer HM, et al. Feasibility of breast-conserving surgery for patients with breast carcinoma associated with nipple discharge. Cancer. Aug. 1. 2004;101(3):508-17. Not eligible target population. [pmid: 15274063].
366 Caceres E, Gamboa M. Treatment of breast cancer by radical surgery: a personal experience of 653 patients with minimal follow-up of 10 years. Semin Surg Oncol. 1990;6(4):207-17. Not eligible target population. [pmid: 2167508].
367 Cady B, Stone MD, Schuler JG, et al. The new era in breast cancer. Invasion, size, and nodal involvement dramatically decreasing as a result of mammographic screening. Arch Surg. Mar. 1996;131(3):301-8. Not eligible outcomes. [pmid: 8611096].
368 Cai N, Koizumi J, Vazquez M. Mammary carcinoma with osteoclast-like giant cells: a study of four cases and a review of literature. Diagn Cytopathol. Oct. 2005;33(4):246-51. Case Reports. [pmid: 16138376].
369 Cajulis RS, Frias-Hidvegi D. Detection of numerical chromosomal abnormalities in malignant cells in fine needle aspirates by fluorescence in situ hybridization of interphase cell nuclei with chromosome-specific probes. Acta Cytol. May–Jun. 1993;37(3):391-6. Not eligible outcomes. [pmid: 8388611].
370 Calais G, Descamps P, Chapet S, et al. Primary chemotherapy and radiosurgical breast-conserving treatment for patients with locally advanced operable breast cancers. Int J Radiat Oncol Biol Phys. Apr. 30. 1993;26(1):37-42. Not eligible target population. [pmid: 8387066].
371 Caldefie-Chezet F, Damez M, de Latour M, et al. Leptin: a proliferative factor for breast cancer? Study on human ductal carcinoma. Biochem Biophys Res Commun. Sep. 2. 2005;334(3):737-41. Not eligible outcomes. [pmid: 16009333].
372 Caldes T, Perez-Segura P, Tosar A, et al. Microsatellite instability correlates with negative expression of estrogen and progesterone receptors in sporadic breast cancer. Teratog Carcinog Mutagen. 2000;20(5):283-91. Not eligible outcomes. [pmid: 10992275].
373 Caliskan M, Gatti G, Sosnovskikh I, et al. Paget’s disease of the breast: the experience of the European Institute of Oncology and review of the literature. Breast Cancer Research & Treatment. Dec. 2008;112(3):513-21. Not eligible target population. [pmid: 18240020].
374 Calitchi E, Otmezguine Y, Feuilhade F, et al. External irradiation prior to conservative surgery for breast cancer treatment. Int J Radiat Oncol Biol Phys. Jul. 1991;21(2):325-9. Not eligible target population. [pmid: 1648043].
375 Caluwe GL, Christiaens MR. Chylous leak: a rare complication after axillary lymph node dissection. Acta Chir Belg. Apr. 2003;103(2):217-8. Case Reports. [pmid: 12768867].
376 Camp ER, McAuliffe PF, Gilroy JS, et al. Minimizing local recurrence after breast conserving therapy using intraoperative shaved margins to determine pathologic tumor clearance. J Am Coll Surg. Dec. 2005;201(6):855-61. Not eligible level of evidence. [pmid: 16310688].
377 Campbell T, Skilton RA, Coombes RC, et al. Isolation of a lactoferrin cDNA clone and its expression in human breast cancer. Br J Cancer. Jan. 1992;65(1):19-26. Not eligible outcomes. [pmid: 1733438].
378 Campo L, Turley H, Han C, et al. Angiogenin is up-regulated in the nucleus and cytoplasm in human primary breast carcinoma and is associated with markers of hypoxia but not survival. J Pathol. Apr. 2005;205(5):585-91. Not eligible outcomes. [pmid: 15776477].
379 Camus MG, Joshi MG, Mackarem G, et al. Ductal carcinoma in situ of the male breast. Cancer. Aug. 15. 1994;74(4):1289-93. Not eligible target population. [pmid: 8055450].
380 Canepa M, Gambini C, Borgiani L, et al. Nucleolar organizer regions: a prognostic factor in infiltrating ductal carcinoma in the breast. Pathologica. Mar–Apr. 1993;85(1096):151-62. Not eligible outcomes. [pmid: 8395684].
381 Cangemi V, Volpino P, Mingazzini P, et al. Role of surgery in ductal carcinoma of the pancreas. Int Surg. Jul–Sep. 1992;77(3):158-63. Not eligible target population. [pmid: 1328103].
382 Canney PA, Priestman TJ, Griffiths T, et al. Randomized trial comparing aminoglutethimide with high-dose medroxyprogesterone acetate in therapy for advanced breast carcinoma. J Natl Cancer Inst. Sep. 21. 1988;80(14):1147-51. Not eligible target population. [pmid: 2970555].
383 Cano A, Coffer AI, Adatia R, et al. Histochemical studies with an estrogen receptor-related protein in human breast tumors. Cancer Res. Dec. 1986;46(12 Pt 1):6475-80. Not eligible outcomes. [pmid: 3536082].
384 Cao D, Lin C, Woo SH, et al. Separate cavity margin sampling at the time of initial breast lumpectomy significantly reduces the need for reexcisions. Am J Surg Pathol. Dec. 2005;29(12):1625-32. Not eligible outcomes. [pmid: 16327435].
385 Cao Y, Paner GP, Kahn LB, et al. Noninvasive carcinoma of the breast: angiogenesis and cell proliferation. Arch Pathol Lab Med. Aug. 2004;128(8):893-6. Not eligible outcomes. [pmid: 15270612].
386 Capobianco G, Spaliviero B, Dessole S, et al. Paget’s disease of the nipple diagnosed by MRI. Arch Gynecol Obstet. Aug. 2006;274(5):316-8. Case Reports. [pmid: 16622685].
387 Cappellani A, Di Vita M, Zanghi A, et al. Ductal carcinoma in situ (DCIS) of the breast: thirty-two consecutive cases under 50 yrs detected by mammography: treatment and results. Ann Ital Chir. Jul–Aug. 2000;71(4):477-81. Not eligible level of evidence. [pmid: 11109672].
388 Caralt M, Bilbao I, Cortes J, et al. Hepatic resection for liver metastases as part of the “oncosurgical” treatment of metastatic breast cancer. Ann Surg Oncol. Oct. 2008;15(10):2804-10. Not eligible target population. [pmid: 18670821].
389 Cardenosa G, Doudna C, Eklund GW. Mucinous (colloid) breast cancer: clinical and mammographic findings in 10 patients. AJR Am J Roentgenol. May. 1994;162(5):1077-9. Not eligible outcomes. [pmid: 8165985].
390 Carder PJ, Garvican J, Haigh I, et al. Needle core biopsy can reliably distinguish between benign and malignant papillary lesions of the breast. Histopathology. Mar. 2005;46(3):320-7. Not eligible outcomes. [pmid: 15720418].
391 Carder PJ, Khan T, Burrows P, et al. Large volume “mammotome” biopsy may reduce the need for diagnostic surgery in papillary lesions of the breast. Journal of clinical pathology. Aug. 2008;61(8):928-33. Not eligible outcomes. [pmid: 18495791].
392 Carder PJ, Murphy CE, Liston JC. Surgical excision is warranted following a core biopsy diagnosis of mucocoele-like lesion of the breast. Histopathology. Aug. 2004;45(2):148-54. Not eligible target population. [pmid: 15279633].
393 Cariaggi MP, Bulgaresi P, Confortini M, et al. Analysis of the causes of false negative cytology reports on breast cancer fine needle aspirates. Cytopathology. Jun. 1995;6(3):156-61. Not eligible outcomes. [pmid: 7669926].
394 Carlson JW, Birdwell RL, Gombos EC, et al. MRI-directed, wire-localized breast excisions: incidence of malignancy and recommendations for pathologic evaluation. Hum Pathol. Dec. 2007;38(12):1754-9. Not eligible exposure. [pmid: 17868777].
395 Carlson KL, Helvie MA, Roubidoux MA, et al. Relationship between mammographic screening intervals and size and histology of ductal carcinoma in situ. AJR Am J Roentgenol. Feb. 1999;172(2):313-7. Not eligible exposure. [pmid: 9930774].
396 Carlsson H, Petersson S, Enerback C. Cluster analysis of S100 gene expression and genes correlating to psoriasin (S100A7) expression at different stages of breast cancer development. Int J Oncol. Dec. 2005;27(6):1473-81. Not eligible outcomes. [pmid: 16273201].
397 Carpenter R, Boulter PS, Cooke T, et al. Management of screen detected ductal carcinoma in situ of the female breast. Br J Surg. Jun. 1989;76(6):564-7. Not eligible level of evidence. [pmid: 2547496].
398 Carpenter R, Gibbs N, Matthews J, et al. Importance of cellular DNA content in pre-malignant breast disease and pre-invasive carcinoma of the female breast. Br J Surg. Oct. 1987;74(10):905-6. Not eligible outcomes. [pmid: 2822199].
399 Carson PL, Adler DD, Fowlkes JB, et al. Enhanced color flow imaging of breast cancer vasculature: continuous wave Doppler and three-dimensional display. J Ultrasound Med. Aug. 1992;11(8):377-85. Not eligible outcomes. [pmid: 1322998].
400 Carson W, Sanchez-Forgach E, Stomper P, et al. Lobular carcinoma in situ: observation without surgery as an appropriate therapy. Ann Surg Oncol. Mar. 1994;1(2):141-6. Not eligible target population. [pmid: 7834439].
401 Carter MR, Hornick JL, Lester S, et al. Spindle cell (sarcomatoid) carcinoma of the breast: a clinicopathologic and immunohistochemical analysis of 29 cases. Am J Surg Pathol. Mar. 2006;30(3):300-9. Not eligible outcomes. [pmid: 16538049].
402 Carty H, McCullough P, Aluwihare N, et al. Breast conserving surgery for breast cancer involving the nipple. Breast. Feb. 2008;17(1):107-10. Case Reports. [pmid: 17892937].
403 Carvalho I, Milanezi F, Martins A, et al. Overexpression of platelet-derived growth factor receptor alpha in breast cancer is associated with tumour progression. Breast Cancer Res. 2005;7(5):R788-95. Not eligible outcomes. [pmid: 16168125].
404 Cascinelli N, Greco M, Morabito A, et al. Comparison of long-term survival of 1986 consecutive patients with breast cancer treated at the National Cancer Institute of Milano, Italy (1971 to 1972 and 1977 to 1978). Cancer. Jul. 2. 1991;68(15):427-34. Not eligible target population. [pmid: 1649000].
405 Casey M, Rosenblatt R, Zimmerman J, et al. Mastectomy without malignancy after carcinoma diagnosed by large-core stereotactic breast biopsy. Mod Pathol. Dec. 1997;10(12):1209-13. Case Reports. [pmid: 9436965].
406 Cassier PA, Ray-Coquard I, Sunyach MP, et al. A phase 2 trial of whole-brain radiotherapy combined with intravenous chemotherapy in patients with brain metastases from breast cancer. Cancer. Nov. 1. 2008;113(9):2532-8. Not eligible target population. [pmid: 18780315].
407 Casso D, Buist DS, Taplin S. Quality of life of 5-10 year breast cancer survivors diagnosed between age 40 and 49. Health Qual Life Outcomes. May. 18. 2004;2:25. Not eligible target population. [pmid: 15149547].
408 Castro NP, Osorio CA, Torres C, et al. Evidence that molecular changes in cells occur before morphological alterations during the progression of breast ductal carcinoma. Breast Cancer Res. 2008;10(5):R87. Not eligible outcomes. [pmid: 18928525].
409 Cataliotti L, Buzdar AU, Noguchi S, et al. Comparison of anastrozole versus tamoxifen as preoperative therapy in postmenopausal women with hormone receptor-positive breast cancer: the Pre-Operative “Arimidex” Compared to Tamoxifen (PROACT) trial. Cancer. May. 15. 2006;106(10):2095-103. Not eligible target population. [pmid: 16598749].
410 Cathcart RS 3rd, Hagerty RC. Preoperative and postoperative considerations in elective breast operations. Ann Plast Surg. Jun. 1989;22(6):533-8. Case Reports. [pmid: 2546477].
411 Cauble WG. Carcinoma of the nipple. Kans Med. May. 1986;87(5):134-5. 47. Case Reports. [pmid: 3012182].
412 Causer PA, Piron CA, Jong RA, et al. MR imaging-guided breast localization system with medial or lateral access. Radiology. Aug. 2006;240(2):369-79. Not eligible exposure. [pmid: 16775219].
413 Cavaliere A, Scheibel M, Bellezza G, et al. Ductal carcinoma in situ with microinvasion: clinicopathologic study and biopathologic profile. Pathol Res Pract. 2006;202(3):131-5. Not eligible level of evidence. [pmid: 16459026].
414 Cawson JN, Malara F, Kavanagh A, et al. Fourteen-gauge needle core biopsy of mammographically evident radial scars: is excision necessary. Cancer. Jan. 15. 2003;97(2):345-51. Not eligible outcomes. [pmid: 12518358].
415 Cecil KM, Schnall MD, Siegelman ES, et al. The evaluation of human breast lesions with magnetic resonance imaging and proton magnetic resonance spectroscopy. Breast Cancer Res Treat. Jul. 2001;68(1):45-54. Not eligible outcomes. [pmid: 11678308].
416 Ceilley E, Jagsi R, Goldberg S, et al. The management of ductal carcinoma in situ in North America and Europe. Results of a survey. Cancer. Nov. 1. 2004;101(9):1958-67. Not eligible outcomes. [pmid: 15389481].
417 Celik A, Kutun S, Pak I, et al. Secretory breast carcinoma with extensive intraductal component: case report. Ultrastruct Pathol. Sep–Dec;. 2004;28:5-6. 361. 3. Case Reports.
418 Cellier C, Cuillerier E, Palazzo L, et al. Intraductal papillary and mucinous tumors of the pancreas: accuracy of preoperative computed tomography, endoscopic retrograde pancreatography and endoscopic ultrasonography, and long-term outcome in a large surgical series. Gastrointest Endosc. Jan. 1998;47(1):42-9. Not eligible target population. [pmid: 9468422].
419 Cellini C, Huston TL, Martins D, et al. Multiple re-excisions versus mastectomy in patients with persistent residual disease following breast conservation surgery. Am J Surg. Jun. 2005;189(6):662-6. Not eligible target population. [pmid: 15910716].
420 Cendan JC, Coco D, Copeland EM 3rd. Accuracy of intraoperative frozen-section analysis of breast cancer lumpectomy-bed margins. J Am Coll Surg. Aug. 2005;201(2):194-8. Not eligible outcomes. [pmid: 16038815].
421 Chadwick DR, Shorthouse AJ. Wire-directed localization biopsy of the breast: an audit of results and analysis of factors influencing therapeutic value in the treatment of breast cancer. Eur J Surg Oncol. Apr. 1997;23(2):128-33. Not eligible outcomes. [pmid: 9158186].
422 Chakrabarti J, Evans AJ, James J, et al. Accuracy of mammography in predicting histological extent of ductal carcinoma in situ (DCIS). Eur J Surg Oncol. Dec. 2006;32(10):1089-92. Not eligible target population. [pmid: 16872800].
423 Chakrabarti J, Turley H, Campo L, et al. The transcription factor DEC1 (stra13, SHARP2) is associated with the hypoxic response and high tumour grade in human breast cancers. Br J Cancer. Aug. 31. 2004;91(5):954-8. Not eligible outcomes. [pmid: 15328513].
424 Chan KC, Knox WF, Gandhi A, et al. Blockade of growth factor receptors in ductal carcinoma in situ inhibits epithelial proliferation. Br J Surg. Mar. 2001;88(3):412-8. Not eligible target population. [pmid: 11260109].
425 Chan MC, Lam HS, Gwi E, et al. Stereotactic fine needle aspiration in the management of mammographic abnormalities detected in breast screening. Aust N Z J Surg. Sep. 1996;66(9):595-7. Not eligible outcomes. [pmid: 8859157].
426 Chan SC, Birdsell DC, Gradeen CY. Urinary excretion of free toluenediamines in a patient with polyurethane-covered breast implants. Clin Chem. Dec. 1991;37(12):2143-5. Case Reports. [pmid: 1662561].
427 Chang E, Johnson N, Webber B, et al. Bilateral reduction mammoplasty in combination with lumpectomy for treatment of breast cancer in patients with macromastia. Am J Surg. May. 2004;187(5):647-50. discussion 50-1. Not eligible target population. [pmid: 15135684].
428 Chang HL, Kish JB, Smith BL, et al. A 16-year-old male with gynecomastia and ductal carcinoma in situ. Pediatr Surg Int. Nov. 2008;24(11):1251-3. Not eligible target population. [pmid: 18766353].
429 Chao KK, Vicini FA, Wallace M, et al. Analysis of treatment efficacy, cosmesis, and toxicity using the MammoSite breast brachytherapy catheter to deliver accelerated partial-breast irradiation: the william beaumont hospital experience. Int J Radiat Oncol Biol Phys. Sep. 1. 2007;69(1):32-40. Not eligible outcomes. [pmid: 17467920].
430 Chapman C, Murray A, Chakrabarti J, et al. Autoantibodies in breast cancer: their use as an aid to early diagnosis. Ann Oncol. May. 2007;18(5):868-73. Not eligible outcomes. [pmid: 17347129].
431 Chapman JA, Meng D, Shepherd L, et al. Competing causes of death from a randomized trial of extended adjuvant endocrine therapy for breast cancer. J Natl Cancer Inst. Feb. 20. 2008;100(4):252-60. Not eligible target population. [pmid: 18270335].
432 Charpin C, Allasia C, Davies JD, et al. Digitization of microcalcifications in breast radiographs. Correlation with pathologic data. Anal Quant Cytol Histol. Aug. 1995;17(4):230-40. Not eligible outcomes. [pmid: 8526947].
433 Charpin C, Bonnier P, Habib MC, et al. X-raying of sliced surgical specimens during surgery: an improvement of the histological diagnosis of impalpable breast lesions with microcalfications. Anticancer Res. Sep–Oct. 1992;12(5):1737-46. Not eligible outcomes. [pmid: 1332583].
434 Chasle J, Delozier T, Denoux Y, et al. Immunohistochemical study of cell cycle regulatory proteins in intraductal breast carcinomas--a preliminary study. Eur J Cancer. Jul. 2003;39(10):1363-9. Not eligible level of evidence. [pmid: 12826038].
435 Chaudary MA, Millis RR, Davies GC, et al. The diagnostic value of testing for occult blood. Ann Surg. Dec. 1982;196(6):651-5. Case Reports. [pmid: 6293391].
436 Chaudary MA, Millis RR, Lane EB, et al. Paget’s disease of the nipple: a ten year review including clinical, pathological, and immunohistochemical findings. Breast Cancer Res Treat. 1986;8(2):139-46. Not eligible target population. [pmid: 2434164].
437 Chaudhuri B, Crist KA, Mucci S, et al. Distribution of estrogen receptor in ductal carcinoma in situ of the breast. Surgery. Feb. 1993;113(2):134-7. Not eligible target population. [pmid: 8381562].
438 Cheek J, Lacy J, Toth-Fejel S, et al. The impact of hormone replacement therapy on the detection and stage of breast cancer. Arch Surg. Sep. 2002;137(9):1015-9. discussion 9-21. Not eligible outcomes. [pmid: 12215151].
439 Chen FM, Hou MF, Chang MY, et al. High frequency of somatic missense mutation of BRCA2 in female breast cancer from Taiwan. Cancer Lett. Apr. 8. 2005;220(2):177-84. Not eligible target population. [pmid: 15766593].
440 Chen JH, Feig B, Agrawal G, et al. MRI evaluation of pathologically complete response and residual tumors in breast cancer after neoadjuvant chemotherapy. Cancer. Jan. 1. 2008;112(1):17-26. Not eligible target population. [pmid: 18000804].
441 Chen JS, Liu WC, Yang KC, et al. Reconstruction with bilateral pedicled TRAM flap for paraffinoma breast. Plast Reconstr Surg. Jan. 2005;115(1):96-104. Not eligible target population. [pmid: 15622238].
442 Chen KT, Chang KJ, Chang YZ, et al. Factors affecting local or regional recurrence in breast cancer. J Formos Med Assoc. Oct. 1991;90(10):986-92. Not eligible target population. [pmid: 1685181].
443 Chen LC, Kurisu W, Ljung BM, et al. Heterogeneity for allelic loss in human breast cancer. J Natl Cancer Inst. Apr. 1. 1992;84(7):506-10. Not eligible outcomes. [pmid: 1312176].
444 Chen M, Palleschi S, Khoynezhad A, et al. Role of primary breast cancer characteristics in predicting positive sentinel lymph node biopsy results: a multivariate analysis. Arch Surg. May. 2002;137(5):606-9. discussion 9-10. Not eligible target population. [pmid: 11982477].
445 Chen SC, Chao TC, Hwang TL, et al. Prognostic factors in node-negative breast cancer patients: the experience in Taiwan. Changgeng Yi Xue Za Zhi. Dec. 1998;21(4):363-70. Not eligible level of evidence. [pmid: 10074719].
446 Chen SC, Cheung YC, Lo YF, et al. Sonographic differentiation of invasive and intraductal carcinomas of the breast. Br J Radiol. Sep. 2003;76(909):600-4. Not eligible outcomes. [pmid: 14500273].
447 Chen SJ, Cheng KS, Dai YC, et al. Quantitatively characterizing the textural features of sonographic images for breast cancer with histopathologic correlation. J Ultrasound Med. May. 2005;24(5):651-61. Not eligible outcomes. [pmid: 15840797].
448 Chen TL, Luo I, Mikhail N, et al. Comparison of flow and image cytometry for DNA content analysis of fresh and formalin-fixed, paraffin-embedded tissue in breast carcinoma. Cytometry. Sep. 15. 1995;22(3):181-9. Not eligible outcomes. [pmid: 8556949].
449 Chen YB, Magpayo J, Rosen PP. Sclerosing adenosis in sentinel axillary lymph nodes from a patient with invasive ductal carcinoma: an unusual variant of benign glandular inclusions. Arch Pathol Lab Med. Sep. 2008;132(9):1439-41. Case Reports. [pmid: 18788857].
450 Chen ZL, Wen DR, Coulson WF, et al. Occult metastases in the axillary lymph nodes of patients with breast cancer node negative by clinical and histologic examination and conventional histology. Dis Markers. Sep–Oct. 1991;9(5):239-48. Not eligible outcomes. [pmid: 1724633].
451 Cheng L, Al-Kaisi NK, Gordon NH, et al. Relationship between the size and margin status of ductal carcinoma in situ of the breast and residual disease. J Natl Cancer Inst. Sep. 17. 1997;89(18):1356-60. Not eligible outcomes. [pmid: 9308705].
452 Cheng MS, Fox J, Hart SA. Impact of core biopsy on the management of screen-detected ductal carcinoma in situ of the breast. ANZ J Surg. Jun. 2003;73(6):404-6. Not eligible outcomes. [pmid: 12801338].
453 Cheung KL, Blamey RW, Robertson JF, et al. Subcutaneous mastectomy for primary breast cancer and ductal carcinoma in situ. Eur J Surg Oncol. Aug. 1997;23(4):343-7. Not eligible level of evidence. [pmid: 9315066].
454 Cheung KL, Owers R, Robertson JF. Endocrine response after prior treatment with fulvestrant in postmenopausal women with advanced breast cancer: experience from a single centre. Endocr Relat Cancer. Mar. 2006;13(1):251-5. Not eligible target population. [pmid: 16601292].
455 Chew I, Ng SB, Tan PH. Test and teach. Number fifty-three. Diagnosis: Spindle cell ductal carcinoma in situ with neuroendocrine differentiation. Pathology. Feb. 2005;37(1):76-9. Case Reports. [pmid: 15875738].
456 Chhieng DC, Fernandez G, Cangiarella JF, et al. Invasive carcinoma in clinically suspicious breast masses diagnosed as adenocarcinoma by fine-needle aspiration. Cancer. Apr. 25. 2000;90(2):96-101. Not eligible outcomes. [pmid: 10794158].
457 Chin Y, Janseens J, Vandepitte J, et al. Phenotypic analysis of tumor-infiltrating lymphocytes from human breast cancer. Anticancer Res. Sep–Oct. 1992;12(5):1463-6. Not eligible outcomes. [pmid: 1332579].
458 Chisholm LJ, Gupta R, Theaker JM, et al. Papillary carcinoma-in-situ of the breast presenting as a fungating lesion. Eur J Surg Oncol. Aug. 2000;26(5):517-8. Case Reports. [pmid: 11016476].
459 Chism DB, Freedman GM, Li T, et al. Re-excision of margins before breast radiation-diagnostic or therapeutic. Int J Radiat Oncol Biol Phys. Aug. 1. 2006;65(5):1416-21. Not eligible target population. [pmid: 16730133].
460 Chivukula M, Haynik DM, Brufsky A, et al. Pleomorphic lobular carcinoma in situ (PLCIS) on breast core needle biopsies: clinical significance and immunoprofile. Am J Surg Pathol. Nov. 2008;32(11):1721-6. Not eligible outcomes. [pmid: 18769331].
461 Chlebowski RT, Hendrix SL, Langer RD, et al. Influence of estrogen plus progestin on breast cancer and mammography in healthy postmenopausal women: the Women’s Health Initiative Randomized Trial. JAMA. Jun. 25. 2003;289(24):3243-53. Not eligible outcomes. [pmid: 12824205].
462 Chlebowski RT, Johnson KC, Kooperberg C, et al. Calcium plus vitamin D supplementation and the risk of breast cancer. J Natl Cancer Inst. Nov. 19. 2008;100(22):1581-91. Not eligible outcomes. [pmid: 19001601].
463 Cho MH, Yoon JH, Jaegal YJ, et al. Expression of cyclooxygenase-2 in breast carcinogenesis and its relation to HER-2/neu and p53 protein expression in invasive ductal carcinoma. Breast. Jun. 2006;15(3):390-8. Not eligible outcomes. [pmid: 16169726].
464 Cho N, Moon WK, Cha JH, et al. Sonographically guided core biopsy of the breast: comparison of 14-gauge automated gun and 11-gauge directional vacuum-assisted biopsy methods. Korean J Radiol. Apr–Jun. 2005;6(2):102-9. Not eligible outcomes. [pmid: 15968149].
465 Choi N, Han BK, Choe YH, et al. Three-phase dynamic breast magnetic resonance imaging with two-way subtraction. J Comput Assist Tomogr. Nov–Dec. 2005;29(6):834-41. Not eligible outcomes. [pmid: 16272861].
466 Choi SH, Barsky SH, Chang HR. Clinicopathologic analysis of sentinel lymph node mapping in early breast cancer. Breast J. May–Jun. 2003;9(3):153-62. Not eligible target population. [pmid: 12752622].
467 Choi YJ, Pinto MM, Hao L, et al. Interobserver variability and aberrant E-cadherin immunostaining of lobular neoplasia and infiltrating lobular carcinoma. Modern Pathology. Oct. 2008;21(10):1224-37. Not eligible target population. [pmid: 18587329].
468 Choi YL, Cho EY, Kim JH, et al. Detection of human papillomavirus DNA by DNA chip in breast carcinomas of Korean women. Tumour Biol. 2007;28(6):327-32. Not eligible outcomes. [pmid: 18391549].
469 Chow CK, Venzon D, Jones EC, et al. Effect of tamoxifen on mammographic density. Cancer Epidemiol Biomarkers Prev. Sep. 2000;9(9):917-21. Not eligible outcomes. [pmid: 11008909].
470 Chow LW, Cheng CW, Wong JL, et al. Serum lipid profiles in patients receiving endocrine treatment for breast cancer--the results from the Celecoxib Anti-Aromatase Neoadjuvant (CAAN) Trial. Biomed Pharmacother. Oct. 2005;59(Suppl 2):S302-5. Not eligible target population. [pmid: 16507398].
471 Chow LW, Wong JL, Toi M. Celecoxib anti-aromatase neoadjuvant (CAAN) trial for locally advanced breast cancer: preliminary report. J Steroid Biochem Mol Biol. Sep. 3. 2003:86-5. 443. 7. Not eligible target population.
472 Choy A, Barr LC, Serpell JW, et al. Radiation-induced sarcoma of the retained breast after conservative surgery and radiotherapy for early breast cancer. Eur J Surg Oncol. Aug. 1993;19(4):376-7. Case Reports. [pmid: 8395411].
473 Christov K, Chew KL, Ljung BM, et al. Cell proliferation in hyperplastic and in situ carcinoma lesions of the breast estimated by in vivo labeling with bromodeoxyuridine. J Cell Biochem Suppl. 1994;19:165-72. Not eligible outcomes. [pmid: 7823588].
474 Chu WC, Lam WW, Pang AL, et al. Computer-assisted detection as a second reader in symptomatic Asian women with palpable breast cancer. Acta Radiol. Apr. 2004;45(2):148-53. Not eligible outcomes. [pmid: 15191097].
475 Chua CL, Tan PK, Chiang G, et al. Breast carcinoma-in-situ: an emerging problem in Singapore. Singapore Med J. Aug. 1992;33(4):383-5. Not eligible target population. [pmid: 1329232].
476 Chuaqui R, Vargas MP, Castiglioni T, et al. Detection of heterozygosity loss in microdissected fine needle aspiration specimens of breast carcinoma. Acta Cytol. Jul–Aug. 1996;40(4):642-8. Not eligible outcomes. [pmid: 8693879].
477 Chun J, El-Tamer M, Joseph KA, et al. Predictors of breast cancer development in a high-risk population. Am J Surg. Oct. 2006;192(4):474-7. Not eligible outcomes. [pmid: 16978952].
478 Chung A, Yu J, Stempel M, et al. Is the “10% rule” equally valid for all subsets of sentinel-node-positive breast cancer patients. Ann Surg Oncol. Oct. 2008;15(10):2728-33. Not eligible target population. [pmid: 18688679].
479 Chung CT, Bogart JA, Adams JF, et al. Increased risk of breast cancer in splenectomized patients undergoing radiation therapy for Hodgkin’s disease. Int J Radiat Oncol Biol Phys. Jan. 15. 1997;37(2):405-9. Not eligible level of evidence. [pmid: 9069314].
480 Chung HJ, Chung HW. Scale issue in fractal analysis of histological specimens. Hum Pathol. Dec. 2008;39(12):1859-60. author reply 60-1. Comment. [pmid: 19010250].
481 Chung MJ, Jung SH, Lee BJ, et al. Inactivation of the PTEN gene protein product is associated with the invasiveness and metastasis, but not angiogenesis, of breast cancer. Pathol Int. Jan. 2004;54(1):10-5. Not eligible outcomes. [pmid: 14674989].
482 Chung TL, Schnaper L, Silverman RP, et al. A novel reconstructive technique following central lumpectomy. Plast Reconstr Surg. Jul. 2006;118(1):23-7. Not eligible target population. [pmid: 16816670].
483 Ciatto S, Morrone D, Catarzi S, et al. Breast cancer: reliability of mammographic appearance as a predictor of hormone receptor status. Radiology. Mar. 1992;182(3):805-8. Not eligible target population. [pmid: 1311118].
484 Cilotti A, Iacconi C, Marini C, et al. Contrast-enhanced MR imaging in patients with BI-RADS 3-5 microcalcifications. Radiol Med (Torino). Mar. 2007;112(2):272-86. Not eligible outcomes. [pmid: 17361370].
485 Cimpean AM, Raica M, Suciu C, et al. Vascular endothelial growth factor A (VEGF A) as individual prognostic factor in invasive breast carcinoma. Rom J Morphol Embryol. 2008;49(3):303-8. Not eligible target population. [pmid: 18758633].
486 Cingoz S, Altungoz O, Canda T, et al. DNA copy number changes detected by comparative genomic hybridization and their association with clinicopathologic parameters in breast tumors. Cancer Genet Cytogenet. Sep. 2003;145(2):108-14. Not eligible outcomes. [pmid: 12935921].
487 Cipolla C, Fricano S, Vieni S, et al. Validity of needle core biopsy in the histological characterisation of mammary lesions. Breast. Feb. 2006;15(1):76-80. Not eligible outcomes. [pmid: 16473738].
488 Cipolla C, Vieni S, Fricano S, et al. The accuracy of sentinel lymph node biopsy in the treatment of multicentric invasive breast cancer using a subareolar injection of tracer. World J Surg. Nov. 2008;32(11):2483-7. Not eligible target population. [pmid: 18726647].
489 Clark CP 3rd, Peters GN, O’Brien KM. Cancer in the augmented breast. Diagnosis and prognosis. Cancer. Oct. 1. 1993;72(7):2170-4. Not eligible exposure. [pmid: 8374874].
490 Clark RM, McCulloch PB, Levine MN, et al. Randomized clinical trial to assess the effectiveness of breast irradiation following lumpectomy and axillary dissection for node-negative breast cancer. J Natl Cancer Inst. May. 6. 1992;84(9):683-9. Not eligible target population. [pmid: 1314910].
491 Claus EB, Petruzella S, Matloff E, et al. Prevalence of BRCA1 and BRCA2 mutations in women diagnosed with ductal carcinoma in situ. JAMA. Feb. 23. 2005;293(8):964-9. Not eligible outcomes. [pmid: 15728167].
492 Claus EB, Stowe M, Carter D, et al. The risk of a contralateral breast cancer among women diagnosed with ductal and lobular breast carcinoma in situ: data. Breast. 2003;12(6):451-6. Not eligible outcomes. [pmid: 14659121].
493 Clauson J, Hsieh YC, Acharya S, et al. Results of the Lynn Sage Second-Opinion Program for local therapy in patients with breast carcinoma. Changes in management and determinants of where care is delivered. Cancer. Feb. 15. 2002;94(4):889-94. Not eligible target population. [pmid: 11920455].
494 Clavien PA, Laffer U, Torhost J, et al. Gastro-intestinal metastases as first clinical manifestation of the dissemination of a breast cancer. Eur J Surg Oncol. Apr. 1990;16(2):121-6. Not eligible target population. [pmid: 2157608].
495 Clay MG. Results of fine-wire localization breast biopsies at the Cancer Control Agency of British Columbia. Can J Surg. Feb. 1990;33(1):17-9. Not eligible target population. [pmid: 2154303].
496 Clayforth C, Fritschi L, McEvoy S, et al. Assessing the effectiveness of a mammography screening service. ANZ J Surg. Aug. 2005;75(8):631-6. Not eligible exposure. [pmid: 16076321].
497 Clayton F. Pathologic correlates of survival in 378 lymph node-negative infiltrating ductal breast carcinomas. Mitotic count is the best single predictor. Cancer. Sep. 15. 1991;68(6):1309-17. Not eligible target population. [pmid: 1651805].
498 Clayton F, Hopkins CL. Pathologic correlates of prognosis in lymph node-positive breast carcinomas. Cancer. Mar. 1. 1993;71(5):1780-90. Not eligible target population. [pmid: 8383579].
499 Clifford EJ, Lugo-Zamudio C. Scintimammography in the diagnosis of breast cancer. Am J Surg. Nov. 1996;172(5):483-6. Not eligible outcomes. [pmid: 8942549].
500 Coates AS, Keshaviah A, Thurlimann B, et al. Five years of letrozole compared with tamoxifen as initial adjuvant therapy for postmenopausal women with endocrine-responsive early breast cancer: update of study BIG 1-98. J Clin Oncol. Feb. 10. 2007;25(5):486-92. Not eligible target population. [pmid: 17200148].
501 Cocconi G, Bisagni G, Ceci G, et al. Low-dose aminoglutethimide with and without hydrocortisone replacement as a first-line endocrine treatment in advanced breast cancer: a prospective randomized trial of the Italian Oncology Group for Clinical Research. J Clin Oncol. Jun. 1992;10(6):984-9. Not eligible target population. [pmid: 1588379].
502 Cocker R, Oktay MH, Sunkara JL, et al. Mechanisms of progression of ductal carcinoma in situ of the breast to invasive cancer. A hypothesis. Med Hypotheses. 2007;69(1):57-63. Medical hypotheses. [pmid: 17257776].
503 Cohen IK. Reconstruction of the nipple-areola by dermabrasion in a black patient. Plast Reconstr Surg. Feb. 1981;67(2):238-9. Case Reports. [pmid: 7465677].
504 Cohen Y, Amir G, Rachmilewitz EA, et al. Sustained complete remission following a combination of very low intensity chemotherapy with rituximab in an elderly patient with Burkitt’s lymphoma. Haematologica. Jan. 2002;87(1):ELT04. Case Reports. [pmid: 11801488].
505 Colandrea JM, Shmookler BM, O’Dowd GJ, et al. Cystic hypersecretory duct carcinoma of the breast. Report of a case with fine-needle aspiration. Arch Pathol Lab Med. May. 1988;112(5):560-3. Case Reports. [pmid: 2833875].
506 Colbassani HJ Jr, Feller WF, Cigtay OS, et al. Mammographic and pathologic correlation of microcalcification in disease of the breast. Surg Gynecol Obstet. Nov. 1982;155(5):689-96. Not eligible outcomes. [pmid: 6291181].
507 Coleman EA, Kessler LG, Wun LM, et al. Trends in the surgical treatment of ductal carcinoma in situ of the breast. Am J Surg. Jul. 1992;164(1):74-6. Not eligible outcomes. [pmid: 1320805].
508 Colleoni M, Rotmensz N, Peruzzotti G, et al. Minimal and small size invasive breast cancer with no axillary lymph node involvement: the need for tailored adjuvant therapies. Ann Oncol. Nov. 2004;15(11):1633-9. Not eligible target population. [pmid: 15520064].
509 Collins LC, Carlo VP, Hwang H, et al. Intracystic papillary carcinomas of the breast: a reevaluation using a panel of myoepithelial cell markers. Am J Surg Pathol. Aug. 2006;30(8):1002-7. Not eligible target population. [pmid: 16861972].
510 Colwell AS, Kukreja J, Breuing KH, et al. Occult breast carcinoma in reduction mammaplasty specimens: 14-year experience. Plast Reconstr Surg. Jun. 2004;113(7):1984-8. Not eligible exposure. [pmid: 15253187].
511 Conde I, Alfaro JM, Fraile B, et al. DAX-1 expression in human breast cancer: comparison with estrogen receptors ER-alpha, ER-beta and androgen receptor status. Breast Cancer Res. 2004;6(3):R140-8. Not eligible outcomes. [pmid: 15084237].
512 Conde I, Paniagua R, Fraile B, et al. Glucocorticoid receptor changes its cellular location with breast cancer development. Histol Histopathol. Jan. 2008;23(1):77-85. Not eligible outcomes. [pmid: 17952860].
513 Connolly JL. Anatomic-pathologic features of breast tumors predictive of outcome in patients treated with breast-conserving surgery and radiation therapy. Front Radiat Ther Oncol. 1993;27:41-51. Secondary data analysis. [pmid: 8389308].
514 Conway WF, Hayes CW, Brewer WH. Occult breast masses: use of a mammographic localizing grid for US evaluation. Radiology. Oct. 1991;181(1):143-6. Not eligible outcomes. [pmid: 1653441].
515 Coombes RC, Chilvers C, Dowsett M, et al. Adjuvant aminoglutethimide therapy for postmenopausal patients with primary breast cancer: progress report. Cancer Res. Aug. 1982;42(8 Suppl):3415s-9s. Not eligible target population. [pmid: 6211228].
516 Coombes RC, Hall E, Gibson LJ, et al. A randomized trial of exemestane after two to three years of tamoxifen therapy in postmenopausal women with primary breast cancer. N Engl J Med. Mar. 11. 2004;350(11):1081-92. Not eligible target population. [pmid: 15014181].
517 Coombes RC, Kilburn LS, Snowdon CF, et al. Survival and safety of exemestane versus tamoxifen after 2-3 years’ tamoxifen treatment (Intergroup Exemestane Study): a randomised controlled trial. Lancet. Feb. 17. 2007;369(9561):559-70. Not eligible target population. [pmid: 17307102].
518 Coombes RC, Powles TJ, Easton D, et al. Adjuvant aminoglutethimide therapy for postmenopausal patients with primary breast cancer. Cancer Res. May. 1. 1987;47(9):2494-7. Not eligible target population. [pmid: 3552216].
519 Coombs NJ, Vassallo PP, Parker AJ, et al. Radiological review of specimen radiographs after breast localisation biopsy is not always necessary. Eur J Surg Oncol. Jun. 2006;32(5):516-9. Not eligible outcomes. [pmid: 16644176].
520 Cooney BS, Orel SG, Schnall MD, et al. Invasive lobular carcinoma in a patient with synchronous ductal carcinoma in situ: detection with MR imaging. AJR Am J Roentgenol. Jun. 1994;162(6):1318-20. Case Reports. [pmid: 8191990].
521 Cooper C, Liu GY, Niu YL, et al. Intermittent hypoxia induces proteasome-dependent down-regulation of estrogen receptor alpha in human breast carcinoma. Clin Cancer Res. Dec. 15. 2004;10(24):8720-7. Not eligible outcomes. [pmid: 15623657].
522 Coover LR, Caravaglia G, Kuhn P. Scintimammography with dedicated breast camera detects and localizes occult carcinoma. J Nucl Med. Apr. 2004;45(4):553-8. Not eligible outcomes. [pmid: 15073249].
523 Cordiner CM, Litherland JC, Young IE. Does the insertion of more than one wire allow successful excision of large clusters of malignant calcification. Clin Radiol. Aug. 2006;61(8):686-90. Not eligible outcomes. [pmid: 16843752].
524 Corkery J, Leonard RC, Henderson IC, et al. Tamoxifen and aminoglutethimide in advanced breast cancer. Cancer Res. Aug. 1982;42(8 Suppl):3409s-14s. Not eligible target population. [pmid: 7044523].
525 Cornett DS, Mobley JA, Dias EC, et al. A novel histology-directed strategy for MALDI-MS tissue profiling that improves throughput and cellular specificity in human breast cancer. Mol Cell Proteomics. Oct. 2006;5(10):1975-83. Not eligible target population. [pmid: 16849436].
526 Cornford EJ, Wilson AR, Athanassiou E, et al. Mammographic features of invasive lobular and invasive ductal carcinoma of the breast: a comparative analysis. Br J Radiol. May. 1995;68(809):450-3. Not eligible outcomes. [pmid: 7788227].
527 Cornu-Labat G, Ghani A, Smith DJ, et al. Small-bowel perforation secondary to metastatic carcinoma of the breast. Am Surg. Apr. 1998;64(4):312. Case Reports. [pmid: 9544140].
528 Cortesi L, Canossi B, De Santis M, et al. Usefulness of breast MRI in a patient with genetic risk. J Exp Clin Cancer Res. Sep. 2002;21(3 Suppl):131-6. Case Reports. [pmid: 12585667].
529 Cossaart N, SantaCruz KS, Preston D, et al. Fatal chemotherapy-induced encephalopathy following high-dose therapy for metastatic breast cancer: a case report and review of the literature. Bone Marrow Transplant. Jan. 2003;31(1):57-60. Case Reports. [pmid: 12621508].
530 Cossu A, Budroni M, Capobianco G, et al. Epidemiology of malignant breast tumors in the province of Sassari (Sardinia, Italy) in the period 1992-2002. Eur J Gynaecol Oncol. 2005;26(5):505-8. Not eligible outcomes. [pmid: 16285566].
531 Costello JF, Fruhwald MC, Smiraglia DJ, et al. Aberrant CpG-island methylation has non-random and tumour-type-specific patterns. Nat Genet. Feb. 2000;24(2):132-8. Not eligible outcomes. [pmid: 10655057].
532 Coulombe G, Tyldesley S, Speers C, et al. Is mastectomy superior to breast-conserving treatment for young women. Int J Radiat Oncol Biol Phys. Apr. 1. 2007;67(5):1282-90. Not eligible target population. [pmid: 17275207].
533 Courtemanche DJ, Worth AJ, Coupland RW, et al. Monoclonal antibody LICR-LON-M8 does not predict the outcome of operable breast cancer. Can J Surg. Feb. 1991;34(1):21-6. Not eligible outcomes. [pmid: 1847654].
534 Couto E, Banks E, Reeves G, et al. Family history and breast cancer tumour characteristics in screened women. Int J Cancer. Dec. 15. 2008;123(12):2950-4. Not eligible outcomes. [pmid: 18816631].
535 Cox CE, Hyacinthe M, Gonzalez RJ, et al. Cytologic evaluation of lumpectomy margins in patients with ductal carcinoma in situ: clinical outcome. Ann Surg Oncol. Dec. 1997;4(8):644-9. Not eligible level of evidence. [pmid: 9416412].
536 Cox D, Bradley S, England D. The significance of mammotome core biopsy specimens without radiographically identifiable microcalcification and their influence on surgical management--a retrospective review with histological correlation. Breast. Apr. 2006;15(2):210-8. Not eligible outcomes. [pmid: 16081287].
537 Cox G, Didlake R, Powers C, et al. Choice of anesthetic technique for needle localized breast biopsy. Am Surg. Jul. 1991;57(7):414-8. Not eligible outcomes. [pmid: 1647712].
538 Coyne JD, Baildam AD, Asbury D. Lymphocytic mastopathy associated with ductal carcinoma in situ of the breast. Histopathology. Jun. 1995;26(6):579-80. Case Reports. [pmid: 7665152].
539 Coyne JD, Dervan PA, Barr L, et al. Mixed apocrine/endocrine ductal carcinoma in situ of the breast coexistent with lobular carcinoma in situ. J Clin Pathol. Jan. 2001;54(1):70-3. Case Reports. [pmid: 11271793].
540 Cramer DW, Petterson KS, Barbieri RL, et al. Reproductive hormones, cancers, and conditions in relation to a common genetic variant of luteinizing hormone. Hum Reprod. Oct. 2000;15(10):2103-7. Not eligible outcomes. [pmid: 11006181].
541 Crile G Jr, Esselstyn CB Jr. Factors influencing local recurrence of cancer after partial mastectomy. Cleve Clin J Med. Mar–Apr. 1990;57(2):143-6. Not eligible target population. [pmid: 2157559].
542 Crisi GM, Mandavilli S, Cronin E, et al. Invasive mammary carcinoma after immediate and short-term follow-up for lobular neoplasia on core biopsy. Am J Surg Pathol. Mar. 2003;27(3):325-33. Not eligible target population. [pmid: 12604888].
543 Crissman JD, Visscher DW, Kubus J. Image cytophotometric DNA analysis of atypical hyperplasias and intraductal carcinomas of the breast. Arch Pathol Lab Med. Dec. 1990;114(12):1249-53. Not eligible outcomes. [pmid: 2174672].
544 Crivellari D, Sun Z, Coates AS, et al. Letrozole compared with tamoxifen for elderly patients with endocrine-responsive early breast cancer: the BIG 1-98 trial. J Clin Oncol. Apr. 20. 2008;26(12):1972-9. Not eligible target population. [pmid: 18332471].
545 Croce MV, Isla-Larrain M, Tur R, et al. Antigenic differences between metastatic cells in bone marrow and primary tumours and the anti-MUC1 humoral immune response induced in breast cancer patients. Clin Exp Metastasis. 2004;21(2):139-47. Not eligible outcomes. [pmid: 15168731].
546 Crombie N, Rampaul RS, Pinder SE, et al. Extent of ductal carcinoma in situ within and surrounding invasive primary breast carcinoma. Br J Surg. Oct. 2001;88(10):1324-9. Not eligible outcomes. [pmid: 11578285].
547 Crowe JP, Patrick RJ, Rybicki LA, et al. A data model to predict HER2 status in breast cancer based on the clinical and pathologic profiles of a large patient population at a single institution. Breast. Dec. 2006;15(6):728-35. Not eligible target population. [pmid: 16716590].
548 Crowe JP, Patrick RJ, Yetman RJ, et al. Nipple-sparing mastectomy update: one hundred forty-nine procedures and clinical outcomes. Arch Surg. Nov. 2008;143(11):1106-10. discussion 10. Not eligible level of evidence. [pmid: 19015470].
549 Cruz NI, Guerrero A, Gonzalez CI. Current findings in the pathological evaluation of breast reduction specimens. Bol Asoc Med P R. Oct. 1989;81(10):387-9. Not eligible outcomes. [pmid: 2610788].
550 Crystal P, Koretz M, Shcharynsky S, et al. Accuracy of sonographically guided 14-gauge core-needle biopsy: results of 715 consecutive breast biopsies with at least two-year follow-up of benign lesions. J Clin Ultrasound. Feb. 2005;33(2):47-52. Not eligible outcomes. [pmid: 15674836].
551 Cserni G. “Revertant” mammary solid papillary carcinoma in lymph node metastasis. Pathol Oncol Res. 2002;8(1):74-7. Case Reports. [pmid: 11994768].
552 Csokay B, Udvarhelyi N, Sulyok Z, et al. High frequency of germ-line BRCA2 mutations among Hungarian male breast cancer patients without family history. Cancer Res. Mar. 1. 1999;59(5):995-8. Not eligible target population. [pmid: 10070953].
553 Cucin RL. Breast reconstruction with a cryopreserved nipple. Ann Plast Surg. Feb. 1982;8(2):163-5. Case Reports. [pmid: 6282175].
554 Cucin RL, Gaston JP. Case report: implantation of breast cancer in a transplanted nipple: a plea for preoperative screening. CA Cancer J Clin. Sep–Oct. 1981;31(5):281-3. Case Reports. [pmid: 6269713].
555 Cui LF, Guo XJ, Wei J, et al. Overexpression of TNF-alpha and TNFRII in invasive micropapillary carcinoma of the breast: clinicopathological correlations. Histopathology. Oct. 2008;53(4):381-8. Not eligible outcomes. [pmid: 18764880].
556 Cuncins-Hearn A, Boult M, Babidge W, et al. National Breast Cancer Audit: ductal carcinoma in situ management in Australia and New Zealand. ANZ J Surg. Jan–Feb. 2007;77(1-2):64-8. Not eligible outcomes. [pmid: 17295824].
557 Cutuli B, Borel C, Dhermain F, et al. Breast cancer occurred after treatment for Hodgkin’s disease: analysis of 133 cases. Radiother Oncol. Jun. 2001;59(3):247-55. Not eligible target population. [pmid: 11369065].
558 Cutuli B, Dhermain F, Borel C, et al. Breast cancer in patients treated for Hodgkin’s disease: clinical and pathological analysis of 76 cases in 63 patients. Eur J Cancer. Dec. 1997;33(14):2315-20. Not eligible level of evidence. [pmid: 9616274].
559 Cutuli B, Teissier E, Piat JM, et al. Radical surgery and conservative treatment of ductal carcinoma in situ of the breast. Eur J Cancer. 1992;28:2-3. 649. 54. Not eligible level of evidence. [pmid: 1567667].
560 Cuzick J. The ATAC trial: the vanguard trial for use of aromatase inhibitors in early breast cancer. Expert Rev Anticancer Ther. Aug. 2007;7(8):1089-94. Not eligible target population. [pmid: 18028017].
561 Cuzick J. IBIS II: a breast cancer prevention trial in postmenopausal women using the aromatase inhibitor anastrozole. Expert Rev Anticancer Ther. Sep. 2008;8(9):1377-85. Not eligible target population. [pmid: 18759690].
562 Cuzick J, Holland R, Barth V, et al. Electropotential measurements as a new diagnostic modality for breast cancer. Lancet. Aug. 1. 1998;352(9125):359-63. Not eligible outcomes. [pmid: 9717923].
563 Cwikla JB, Buscombe JR, Holloway B, et al. Can scintimammography with (99m)Tc-MIBI identify multifocal and multicentric primary breast cancer. Nucl Med Commun. Dec. 2001;22(12):1287-93. Not eligible outcomes. [pmid: 11711898].
564 Cwikla JB, Buscombe JR, Kolasinska AD, et al. Correlation between uptake of Tc-99m sestaMIBI and prognostic factors of breast cancer. Anticancer Res. May–Jun. 1999;19(3B):2299-304. Not eligible outcomes. [pmid: 10472348].
565 Dabbs DJ. Ductal carcinoma of breast: nuclear grade as a predictor of S-phase fraction. Hum Pathol. Jun. 1993;24(6):652-6. Not eligible outcomes. [pmid: 8389317].
566 Dabbs DJ, Bhargava R, Chivukula M. Lobular versus ductal breast neoplasms: the diagnostic utility of p120 catenin. Am J Surg Pathol. Mar. 2007;31(3):427-37. Not eligible target population. [pmid: 17325485].
567 Dabbs DJ, Carter G, Fudge M, et al. Molecular alterations in columnar cell lesions of the breast. Mod Pathol. Mar. 2006;19(3):344-9. Not eligible outcomes. [pmid: 16400324].
568 Dabbs DJ, Chivukula M, Carter G, et al. Basal phenotype of ductal carcinoma in situ: recognition and immunohistologic profile. Mod Pathol. Nov. 2006;19(11):1506-11. Not eligible outcomes. [pmid: 16941011].
569 Dabski K, Stoll HL Jr. Paget’s disease of the breast presenting as a cutaneous horn. J Surg Oncol. Aug. 1985;29(4):237-9. Not eligible target population. [pmid: 3001425].
570 Dadmanesh F, Fan X, Dastane A, et al. Comparative analysis of size estimation by mapping and counting number of blocks with ductal carcinoma in situ in breast excision specimens. Arch Pathol Lab Med. Jan. 2009;133(1):26-30. Not eligible outcomes. [pmid: 19123732].
571 D’Agincourt L. Early detection of DCIS broadens therapy options. Diagn Imaging (San Franc). Sep. 1992;14(9):80-5. Comment.
572 Dahlstrom JE, Jain S. Histological correlation of mammographically detected microcalcifications in stereotactic core biopsies. Pathology. Nov. 2001;33(4):444-8. Not eligible outcomes. [pmid: 11827410].
573 D’Aiuto G, Del Vecchio S, Mansi L, et al. Malignant melanoma of the nipple: a case studied with radiolabeled monoclonal antibody. Tumori. Oct. 31. 1991;77(5):449-51. Not eligible target population. [pmid: 1664156].
574 Dalberg K, Hellborg H, Warnberg F. Paget’s disease of the nipple in a population based cohort. Breast Cancer Research & Treatment. Sep. 2008;111(2):313-9. Not eligible target population. [pmid: 17952590].
575 Daley J, Delbanco L, Walzer J. A 47-year-old woman with ductal carcinoma in situ, 1 year later. JAMA. Aug. 14. 1996;276(6):491. Case Reports. [pmid: 8691559].
576 Dall P, Heider KH, Sinn HP, et al. Comparison of immunohistochemistry and RT-PCR for detection of CD44v-expression, a new prognostic factor in human breast cancer. Int J Cancer. Feb. 8. 1995;60(4):471-7. Not eligible outcomes. [pmid: 7530237].
577 Damascelli B, Frigerio LF, Patelli G, et al. Stereotactic breast biopsy: en bloc excision of microcalcifications with a large-bore cannula device. AJR Am J Roentgenol. Oct. 1999;173(4):895-900. Not eligible outcomes. [pmid: 10511143].
578 Danforth DN Jr, Abati A, Filie A, et al. Combined breast ductal lavage and ductal endoscopy for the evaluation of the high-risk breast: a feasibility study. J Surg Oncol. Dec. 1. 2006;94(7):555-64. Not eligible outcomes. [pmid: 17048242].
579 Daniel BL, Birdwell RL, Butts K, et al. Freehand iMRI-guided large-gauge core needle biopsy: a new minimally invasive technique for diagnosis of enhancing breast lesions. J Magn Reson Imaging. Jun. 2001;13(6):896-902. Not eligible target population. [pmid: 11382950].
580 Daniel BL, Yen YF, Glover GH, et al. Breast disease: dynamic spiral MR imaging. Radiology. Nov. 1998;209(2):499-509. Not eligible outcomes. [pmid: 9807580].
581 Danikas D, Matthews WE, Averbach DJ. Mammary endocrine ductal carcinoma in situ: a case report. Am Surg. Dec. 2000;66(12):1163-4. Case Reports. [pmid: 11149590].
582 Dankof A, Fritzsche FR, Dahl E, et al. KPNA2 protein expression in invasive breast carcinoma and matched peritumoral ductal carcinoma in situ. Virchows Arch. Nov. 2007;451(5):877-81. Not eligible outcomes. [pmid: 17899179].
583 Darling ML, Smith DN, Lester SC, et al. Atypical ductal hyperplasia and ductal carcinoma in situ as revealed by large-core needle breast biopsy: results of surgical excision. AJR Am J Roentgenol. Nov. 2000;175(5):1341-6. Not eligible outcomes. [pmid: 11044038].
584 Darvishian F, Ginsberg MS, Klimstra DS, et al. Carcinoid tumorlets simulate pulmonary metastases in women with breast cancer. Hum Pathol. Jul. 2006;37(7):839-44. Case Reports. [pmid: 16784983].
585 Datrice N, Narula N, Maggard M, et al. Do breast columnar cell lesions with atypia need to be excised. Am Surg. Oct. 2007;73(10):984-6. Not eligible outcomes. [pmid: 17983063].
586 Datta D, Flaxenburg JA, Laxmanan S, et al. Ras-induced modulation of CXCL10 and its receptor splice variant CXCR3-B in MDA-MB-435 and MCF-7 cells: relevance for the development of human breast cancer. Cancer Res. Oct. 1. 2006;66(19):9509-18. Not eligible outcomes. [pmid: 17018607].
587 David J, Trop I, Lalonde L. Breast procedures guided by magnetic resonance imaging. Can Assoc Radiol J. Dec. 2005;56(5):309-18. No associative hypothesis tested. [pmid: 16579025].
588 Davis MD, Alexander JL, Prawer SE. Pyoderma gangrenosum of the breasts precipitated by breast surgery. J Am Acad Dermatol. Aug. 2006;55(2):317-20. Case Reports. [pmid: 16844520].
589 Davis WG, Hennessy B, Babiera G, et al. Metaplastic sarcomatoid carcinoma of the breast with absent or minimal overt invasive carcinomatous component: a misnomer. Am J Surg Pathol. Nov. 2005;29(11):1456-63. Not eligible target population. [pmid: 16224212].
590 Dawson AE, Mulford DK, Sheils LA. The cytopathology of proliferative breast disease. Comparison with features of ductal carcinoma in situ. Am J Clin Pathol. Apr. 1995;103(4):438-42. Not eligible outcomes. [pmid: 7726140].
591 Dawson PJ, Maloney T, Gimotty P, et al. Bilateral breast cancer: one disease or two. Breast Cancer Res Treat. Nov. 1991;19(3):233-44. Not eligible outcomes. [pmid: 1663803].
592 De Berardis B, Torresini G, Marinelli S, et al. Giant metastatic small bowel and mesentery localization and pleural metastases secondary to breast cancer. Case report. Acta Biomed. Aug. 2003;74(2):93-6. Case Reports. [pmid: 14509918].
593 de Candia P, Akram M, Benezra R, et al. Id4 messenger RNA and estrogen receptor expression: inverse correlation in human normal breast epithelium and carcinoma. Hum Pathol. Aug. 2006;37(8):1032-41. Not eligible outcomes. [pmid: 16867866].
594 De Cesare A, Burza A, Fiori E, et al. Assessment of surgical treatment in elderly patients with breast cancer. Tumori. May–Jun. 2008;94(3):314-9. Not eligible target population. [pmid: 18705397].
595 de Csepel J, Tartter PI, Gajdos C. When not to give radiation therapy after breast conservation surgery for breast cancer. J Surg Oncol. Aug. 2000;74(4):273-7. Not eligible level of evidence. [pmid: 10962459].
596 de Gara CJ, Gagic N, Arnold A, et al. Toxic megacolon associated with anticancer chemotherapy. Can J Surg. Aug. 1991;34(4):339-41. Case Reports. [pmid: 1651153].
597 de Jong E, Peterse JL, van Dongen JA. Recurrence after breast ablation for ductal carcinoma in situ. Eur J Surg Oncol. Feb. 1992;18(1):64-6. Case Reports. [pmid: 1310646].
598 de Koning HJ, Draisma G, Fracheboud J, et al. Overdiagnosis and overtreatment of breast cancer: microsimulation modelling estimates based on observed screen and clinical data. Breast Cancer Res. 2006;8(1):202. Not eligible outcomes. [pmid: 16524452].
599 de Koning HJ, van Dongen JA, van der Maas PJ. Changes in use of breast-conserving therapy in years 1978-2000. Br J Cancer. Dec. 1994;70(6):1165-70. Not eligible outcomes. [pmid: 7981070].
600 de Mascarel I, MacGrogan G, Mathoulin-Pelissier S, et al. Epithelial atypia in biopsies performed for microcalcifications. practical considerations about 2,833 serially sectioned surgical biopsies with a long follow-up. Virchows Arch. Jul. 2007;451(1):1-10. Not eligible target population. [pmid: 17551752].
601 de Mascarel I, Trojani M, Coindre JM, et al. The incidence of cancer in contralateral reduction mammaplasty after mastectomy and reconstruction of the removed breast. Tumori. Apr. 30. 1986;72(2):183-6. Not eligible exposure. [pmid: 3705192].
602 De Morgan S, Redman S, White KJ, et al. “Well, have I got cancer or haven’t I?” The psycho-social issues for women diagnosed with ductal carcinoma in situ. Health Expect. Dec. 2002;5(4):310-8. Not eligible outcomes. [pmid: 12460220].
603 De Potter CR, Beghin C, Makar AP, et al. The neu-oncogene protein as a predictive factor for haematogenous metastases in breast cancer patients. Int J Cancer. Jan. 15. 1990;45(1):55-8. Not eligible outcomes. [pmid: 2153640].
604 De Potter CR, Beghin C, Praet MM, et al. CEA and HMFG in hyperplastic and malignant lesions of the breast. Pathol Res Pract. Jun. 1988;183(3):271-6. Not eligible outcomes. [pmid: 2843840].
605 De Potter CR, Praet MM, Slavin RE, et al. Feulgen DNA content and mitotic activity in proliferative breast disease. A comparison with ductal carcinoma in situ. Histopathology. Dec. 1987;11(12):1307-19. Not eligible outcomes. [pmid: 2831133].
606 De Potter CR, Schelfhout AM, Verbeeck P, et al. neu overexpression correlates with extent of disease in large cell ductal carcinoma in situ of the breast. Hum Pathol. Jun. 1995;26(6):601-6. Not eligible outcomes. [pmid: 7774888].
607 De Potter CR, Van Daele S, Van de Vijver MJ, et al. The expression of the neu oncogene product in breast lesions and in normal fetal and adult human tissues. Histopathology. Oct. 1989;15(4):351-62. Not eligible target population. [pmid: 2572531].
608 de Roos MA, Groote AD, Pijnappel RM, et al. Small size ductal carcinoma in situ of the breast: predictors of positive margins after local excision. Int Surg. Mar–Apr. 2006;91(2):100-6. Not eligible outcomes. [pmid: 16774181].
609 de Roos MA, Pijnappel RM, Groote AD, et al. Ductal carcinoma in situ presenting as microcalcifications: the effect of stereotactic large-core needle biopsy on surgical therapy. Breast. Dec. 2004;13(6):461-7. Not eligible outcomes. [pmid: 15563852].
610 de Roos MA, van der Vegt B, de Vries J, et al. Pathological and biological differences between screen-detected and interval ductal carcinoma in situ of the breast. Ann Surg Oncol. Jul. 2007;14(7):2097-104. Not eligible outcomes. [pmid: 17453296].
611 de Roos MA, van der Vegt B, Peterse JL, et al. The expression pattern of MUC1 (EMA) is related to tumour characteristics and clinical outcome in ‘pure’ ductal carcinoma in situ of the breast. Histopathology. Aug. 2007;51(2):227-38. Not eligible outcomes. [pmid: 17650217].
612 de Silva D, Gilbert F, Needham G, et al. Identification of women at high genetic risk of breast cancer through the National Health Service Breast Screening Programme (NHSBSP). J Med Genet. Nov. 1995;32(11):862-6. Case Reports. [pmid: 8592328].
613 Dean JC, Ilvento CC. Improved cancer detection using computer-aided detection with diagnostic and screening mammography: prospective study of 104 cancers. AJR Am J Roentgenol. Jul. 2006;187(1):20-8. Not eligible outcomes. [pmid: 16794150].
614 Decaussin M, Laville M, Mathevet P, et al. Paget’s disease versus Toker cell hyperplasia in a supernumerary nipple. Virchows Arch. Mar. 1998;432(3):289-91. Not eligible target population. [pmid: 9532009].
615 Decensi A, Zanardi S, Argusti A, et al. Fenretinide and risk reduction of second breast cancer. Nat Clin Pract Oncol. Feb. 2007;4(2):64-5. Comment. [pmid: 17259924].
616 Deckers PJ, Ricci A Jr. Evolving strategies in operable breast cancer. 1. Noninvasive or occult malignancies. Hosp Pract (Off Ed). Sep. 15. 1991;26(9):103-14. Case Reports. [pmid: 1654339].
617 Degnim AC, Oh K, Cimmino VM, et al. Is blue dye indicated for sentinel lymph node biopsy in breast cancer patients with a positive lymphoscintigram. Ann Surg Oncol. Sep. 2005;12(9):712-7. Not eligible target population. [pmid: 16079955].
618 Degrell I. Aspiration cytology of breast carcinoma. Acta Morphol Acad Sci Hung. 1982;30:3-4. 277. 88. Not eligible outcomes.
619 del Moral R, Ruiz de Almodovar JM, Fernandez JC, et al. Relationship between proliferative activity and cellular hormono-dependence in the MCF-7 breast cancer cell line. Rev Esp Fisiol. Sep. 1990;46(3):247-53. Not eligible outcomes. [pmid: 1965340].
620 Delaloye JF, De Grandi P, de Landtsheer JP, et al. The carcinomas in situ of the breast. M‚d Hyg. 1998;56:263-5. Language.
621 DeLoach J, Hayes J, Stair M, et al. Radiological case of the month Ductal carcinoma in situ. J Ark Med Soc. Jan. 1996;92(8):415-8. Case Reports. [pmid: 8582890].
622 Demeter JG, Waterman NG, Verdi GD. Familial male breast carcinoma. Cancer. May. 15. 1990;65(10):2342-3. Case Reports. [pmid: 2161282].
623 DeNardo SJ, Warhoe KA, O’Grady LF, et al. Radioimmunotherapy for breast cancer: treatment of a patient with I-131 L6 chimeric monoclonal antibody. Int J Biol Markers. Oct–Dec. 1991;6(4):221-30. Case Reports. [pmid: 1665501].
624 Denewer A, El-Etribi K, Nada N, et al. The role and limitations of mammary ductoscope in management of pathologic nipple discharge. Breast J. Sep–Oct. 2008;14(5):442-9. Not eligible target population. [pmid: 18673337].
625 Derenzini M, Betts CM, Trere D, et al. Diagnostic value of silver-stained interphasic nucleolar organizer regions in breast tumors. Ultrastruct Pathol. May–Jun. 1990;14(3):233-45. Not eligible outcomes. [pmid: 1694051].
626 Dershaw DD, Abramson A, Kinne DW. Ductal carcinoma in situ: mammographic findings and clinical implications. Radiology. Feb. 1989;170(2):411-5. Not eligible outcomes. [pmid: 2536185].
627 Dershaw DD, Morris EA, Liberman L, et al. Nondiagnostic stereotaxic core breast biopsy: results of rebiopsy. Radiology. Feb. 1996;198(2):323-5. Not eligible outcomes. [pmid: 8596825].
628 Dershaw DD, Yahalom J, Petrek JA. Breast carcinoma in women previously treated for Hodgkin disease: mammographic evaluation. Radiology. Aug. 1992;184(2):421-3. Not eligible target population. [pmid: 1320281].
629 Deschenes L, Jacob S, Fabia J, et al. Beware of breast fibroadenomas in middle-aged women. Can J Surg. Jul. 1985;28(4):372-4. Case Reports. [pmid: 2990650].
630 Desmetz C, Bibeau F, Boissiere F, et al. Proteomics-based identification of HSP60 as a tumor-associated antigen in early stage breast cancer and ductal carcinoma in situ. J Proteome Res. Sep. 2008;7(9):3830-7. Not eligible outcomes. [pmid: 18683965].
631 Destounis SV, DiNitto P, Logan-Young W, et al. Can computer-aided detection with double reading of screening mammograms help decrease the false-negative rate? Initial experience. Radiology. Aug. 2004;232(2):578-84. Not eligible outcomes. [pmid: 15229350].
632 Detraux P, Benmussa M, Tristant H, et al. Breast disease in the male: galactographic evaluation. Radiology. Mar. 1985;154(3):605-6. Not eligible target population. [pmid: 2982173].
633 Deutsch M. Ductal carcinoma in situ recurrent on the chest wall after mastectomy. Clin Oncol (R Coll Radiol). 1999;11(1):61-2. Case Reports. [pmid: 10194590].
634 Deutsch M. Radiotherapy after lumpectomy for breast cancer in very old women. Am J Clin Oncol. Feb. 2002;25(1):48-9. Not eligible target population. [pmid: 11823696].
635 Deutsch M. Repeat high-dose external beam irradiation for in-breast tumor recurrence after previous lumpectomy and whole breast irradiation. Int J Radiat Oncol Biol Phys. Jul. 1. 2002;53(3):687-91. Not eligible target population. [pmid: 12062613].
636 Dhingra K, Sneige N, Pandita TK, et al. Quantitative analysis of chromosome in situ hybridization signal in paraffin-embedded tissue sections. Cytometry. Jun. 1. 1994;16(2):100-12. Not eligible outcomes. [pmid: 7924678].
637 Di Cristofano C, Mrad K, Zavaglia K, et al. Papillary lesions of the breast: a molecular progression. Breast Cancer Res Treat. Mar. 2005;90(1):71-6. Not eligible target population. [pmid: 15770529].
638 Di Modugno F, Mottolese M, Di Benedetto A, et al. The cytoskeleton regulatory protein hMena (ENAH) is overexpressed in human benign breast lesions with high risk of transformation and human epidermal growth factor receptor-2-positive/hormonal receptor-negative tumors. Clin Cancer Res. Mar. 1. 2006;12(5):1470-8. Not eligible outcomes. [pmid: 16533770].
639 Di Pietro S, Azzarelli A, Merson M. Unexpected breast cancer detection after outpatient biopsy for benign lesion. Tumori. Oct. 31. 1981;67(5):437-41. Not eligible target population. [pmid: 6275586].
640 Di Tommaso L, Franchi G, Destro A, et al. Toker cells of the breast. Morphological and immunohistochemical characterization of 40 cases. Human pathology. Sep. 2008;39(9):1295-300. Not eligible outcomes. [pmid: 18614197].
641 Diallo R, Rody A, Jackisch C, et al. C-KIT expression in ductal carcinoma in situ of the breast: co-expression with HER-2/neu. Hum Pathol. Feb. 2006;37(2):205-11. Not eligible outcomes. [pmid: 16426921].
642 Diaz LK, Wiley EL, Venta LA. Are malignant cells displaced by large-gauge needle core biopsy of the breast. AJR Am J Roentgenol. Nov. 1999;173(5):1303-13. Not eligible outcomes. [pmid: 10541110].
643 Diaz NM, Mayes JR, Vrcel V. Breast epithelial cells in dermal angiolymphatic spaces: a manifestation of benign mechanical transport. Hum Pathol. Mar. 2005;36(3):310-3. Case Reports. [pmid: 15791577].
644 Diaz NM, Palmer JO, McDivitt RW. Carcinoma arising within fibroadenomas of the breast. A clinicopathologic study of 105 patients. Am J Clin Pathol. May. 1991;95(5):614-22. Not eligible target population. [pmid: 1850948].
645 Dickler M. Do biomarker changes during neoadjuvant endocrine therapy reflect breast tumor receptor status. Nat Clin Pract Oncol. Oct. 2005;2(10):498-9. Not eligible target population. [pmid: 16205767].
646 DiCostanzo D, Rosen PP, Gareen I, et al. Prognosis in infiltrating lobular carcinoma. An analysis of “classical” and variant tumors. Am J Surg Pathol. Jan. 1990;14(1):12-23. Not eligible target population. [pmid: 2153007].
647 Diller L, Medeiros Nancarrow C, Shaffer K, et al. Breast cancer screening in women previously treated for Hodgkin’s disease: a prospective cohort study. J Clin Oncol. Apr. 15. 2002;20(8):2085-91. Not eligible level of evidence. [pmid: 11956269].
648 Dillon DC, Easley SE, Asch BB, et al. Differential expression of high-affinity melatonin receptors (MT1) in normal and malignant human breast tissue. Am J Clin Pathol. Sep. 2002;118(3):451-8. Not eligible outcomes. [pmid: 12219788].
649 Dillon MF, Maguire AA, McDermott EW, et al. Needle core biopsy characteristics identify patients at risk of compromised margins in breast conservation surgery. Modern Pathology. Jan. 2008;21(1):39-45. Not eligible exposure. [pmid: 17948023].
650 Dillon MF, Mc Dermott EW, O’Doherty A, et al. Factors affecting successful breast conservation for ductal carcinoma in situ. Ann Surg Oncol. May. 2007;14(5):1618-28. Not eligible outcomes. [pmid: 17443388].
651 Dillon MF, McDermott EW, Hill AD, et al. Predictive value of breast lesions of “uncertain malignant potential” and “suspicious for malignancy” determined by needle core biopsy. Ann Surg Oncol. Feb. 2007;14(2):704-11. Not eligible outcomes. [pmid: 17151788].
652 Dillon MF, McDermott EW, Quinn CM, et al. Predictors of invasive disease in breast cancer when core biopsy demonstrates DCIS only. J Surg Oncol. Jun. 1. 2006;93(7):559-63. Not eligible outcomes. [pmid: 16705731].
653 Dillon MF, Quinn CM, McDermott EW, et al. Diagnostic accuracy of core biopsy for ductal carcinoma in situ and its implications for surgical practice. J Clin Pathol. Jul. 2006;59(7):740-3. Not eligible outcomes. [pmid: 16803949].
654 Diment J, Yurim O, Pappo O. Infantile hemangioendothelioma of the liver in an adult. Arch Pathol Lab Med. Jul. 2001;125(7):931-2. Case Reports. [pmid: 11419979].
655 Ding L, Kleer CG. Enhancer of Zeste 2 as a marker of preneoplastic progression in the breast. Cancer Res. Oct. 1. 2006;66(19):9352-5. Not eligible outcomes. [pmid: 17018586].
656 Dinkel HP, Gassel AM, Muller T, et al. Galactography and exfoliative cytology in women with abnormal nipple discharge. Obstet Gynecol. Apr. 2001;97(4):625-9. Not eligible outcomes. [pmid: 11275040].
657 Dinkel HP, Gassel AM, Tschammler A. Is the appearance of microcalcifications on mammography useful in predicting histological grade of malignancy in ductal cancer in situ. Br J Radiol. Sep. 2000;73(873):938-44. Not eligible outcomes. [pmid: 11064645].
658 DiPiro PJ, Meyer JE, Denison CM, et al. Image-guided core breast biopsy of ductal carcinoma in situ presenting as a non-calcified abnormality. Eur J Radiol. Jun. 1999;30(3):231-6. Not eligible outcomes. [pmid: 10452723].
659 Dirix LY, Ignacio J, Nag S, et al. Treatment of advanced hormone-sensitive breast cancer in postmenopausal women with exemestane alone or in combination with celecoxib. J Clin Oncol. Mar. 10. 2008;26(8):1253-9. Not eligible target population. [pmid: 18323548].
660 Disa JJ, Cordeiro PG, Heerdt AH, et al. Skin-sparing mastectomy and immediate autologous tissue reconstruction after whole-breast irradiation. Plast Reconstr Surg. Jan. 2003;111(1):118-24. Not eligible level of evidence. [pmid: 12496572].
661 Dittrich C, Baur M, Mader R, et al. Phase I–II study on weekly administration of pirarubicin in patients with metastatic breast cancer. Am J Clin Oncol. 1990;13(Suppl 1):S29-39. Not eligible target population. [pmid: 1963274].
662 Dixon AR, Ellis IO, Elston CW, et al. A comparison of the clinical metastatic patterns of invasive lobular and ductal carcinomas of the breast. Br J Cancer. Apr. 1991;63(4):634-5. Not eligible outcomes. [pmid: 1850613].
663 Dixon AR, Galea MH, Ellis IO, et al. Paget’s disease of the nipple. Br J Surg. Jun. 1991;78(6):722-3. Not eligible target population. [pmid: 1648987].
664 Dixon JM, Faratian D, White S, et al. DCIS and aromatase inhibitors. J Steroid Biochem Mol Biol. Aug–Sep. 2007;106(1-5):173-9. Not eligible target population. [pmid: 17604618].
665 Dixon JM, Jackson J, Hills M, et al. Anastrozole demonstrates clinical and biological effectiveness in oestrogen receptor-positive breast cancers, irrespective of the erbB2 status. Eur J Cancer. Dec. 2004;40(18):2742-7. Not eligible target population. [pmid: 15571956].
666 Dixon JM, Ravi Sekar O, Walsh J, et al. Specimen-orientated radiography helps define excision margins of malignant lesions detected by breast screening. Br J Surg. Aug. 1993;80(8):1001-2. Not eligible outcomes. [pmid: 8155117].
667 Dixon JM, Renshaw L, Bellamy C, et al. The effects of neoadjuvant anastrozole (Arimidex) on tumor volume in postmenopausal women with breast cancer: a randomized, double-blind, single-center study. Clin Cancer Res. Jun. 2000;6(6):2229-35. Not eligible target population. [pmid: 10873072].
668 Dixon JM, Renshaw L, Young O, et al. Letrozole suppresses plasma estradiol and estrone sulphate more completely than anastrozole in postmenopausal women with breast cancer. J Clin Oncol. Apr. 1. 2008;26(10):1671-6. Not eligible target population. [pmid: 18375896].
669 Dmytrasz K, Tartter PI, Mizrachy H, et al. The significance of atypical lobular hyperplasia at percutaneous breast biopsy. Breast J. Jan–Feb. 2003;9(1):10-2. Not eligible outcomes. [pmid: 12558664].
670 Dodwell D, Clements K, Lawrence G, et al. Radiotherapy following breast-conserving surgery for screen-detected ductal carcinoma in situ: indications and utilisation in the UK. Interim findings from the Sloane Project. Br J Cancer. Sep. 17. 2007;97(6):725-9. Not eligible outcomes. [pmid: 17848911].
671 Dogan BE, Whitman GJ, Middleton LP, et al. Intracystic papillary carcinoma of the breast. AJR Am J Roentgenol. Jul. 2003;181(1):186. Case Reports. [pmid: 12818855].
672 Domagala W, Lasota J, Dukowicz A, et al. Vimentin expression appears to be associated with poor prognosis in node-negative ductal NOS breast carcinomas. Am J Pathol. Dec. 1990;137(6):1299-304. Not eligible target population. [pmid: 1701960].
673 Domagala W, Striker G, Szadowska A, et al. Cathepsin D in invasive ductal NOS breast carcinoma as defined by immunohistochemistry. No correlation with survival at 5 years. Am J Pathol. Nov. 1992;141(5):1003-12. Not eligible target population. [pmid: 1332483].
674 Dombernowsky P, Smith I, Falkson G, et al. Letrozole, a new oral aromatase inhibitor for advanced breast cancer: double-blind randomized trial showing a dose effect and improved efficacy and tolerability compared with megestrol acetate. J Clin Oncol. Feb. 1998;16(2):453-61. Not eligible target population. [pmid: 9469328].
675 Dominguez F, Magdalena C, Cancio E, et al. Tissue concentrations of prothymosin alpha: a novel proliferation index of primary breast cancer. Eur J Cancer. 1993;29A(6):893-7. Not eligible outcomes. [pmid: 8387320].
676 Domoto H, Tsuda H, Miyakawa K, et al. Invasive ductal carcinoma associated with tubular adenoma of the breast. Pathol Int. Mar. 2002;52(3):244-8. Case Reports. [pmid: 11972869].
677 Done SJ, Arneson CR, Ozcelik H, et al. P53 protein accumulation in non-invasive lesions surrounding p53 mutation positive invasive breast cancers. Breast Cancer Res Treat. Jan. 2001;65(2):111-8. Not eligible outcomes. [pmid: 11261826].
678 Dong M, Nio Y, Guo KJ, et al. Epidermal growth factor and its receptor as prognostic indicators in Chinese patients with pancreatic cancer. Anticancer Res. Nov–Dec. 1998;18(6B):4613-9. Not eligible target population. [pmid: 9891528].
679 Dooley WC. Routine operative breast endoscopy for bloody nipple discharge. Ann Surg Oncol. Nov. 2002;9(9):920-3. Not eligible target population. [pmid: 12417516].
680 Dooley WC. Routine operative breast endoscopy during lumpectomy. Ann Surg Oncol. Jan–Feb. 2003;10(1):38-42. Not eligible outcomes. [pmid: 12513958].
681 Doren E, Hulvat M, Norton J, et al. Predicting cancer on excision of atypical ductal hyperplasia. Am J Surg. Mar. 2008;195(3):358-61. discussion 61-2. Not eligible outcomes. [pmid: 18206849].
682 Dotto J, Kluk M, Geramizadeh B, et al. Frequency of clinically occult intraepithelial and invasive neoplasia in reduction mammoplasty specimens: a study of 516 cases. Int J Surg Pathol. Jan. 2008;16(1):25-30. Not eligible outcomes. [pmid: 18203780].
683 Douglas-Jones AG, Pace DP. Pathology of R4 spiculated lesions in the breast screening programme. Histopathology. Mar. 1997;30(3):214-20. Not eligible outcomes. [pmid: 9088949].
684 Dowlatshahi K, Francescatti DS, Bloom KJ. Laser therapy for small breast cancers. Am J Surg. Oct. 2002;184(4):359-63. Not eligible target population. [pmid: 12383903].
685 Dowlatshahi K, Jokich PM, Kluskens LF, et al. A prospective study of double diagnosis of nonpalpable lesions of the breast. Surg Gynecol Obstet. Feb. 1991;172(2):121-4. Not eligible outcomes. [pmid: 1846452].
686 Dowlatshahi K, Snider HC, Gittleman MA, et al. Early experience with balloon brachytherapy for breast cancer. Arch Surg. Jun. 2004;139(6):603-7. discussion 7-8. Not eligible target population. [pmid: 15197085].
687 Dowsett M, Allred C, Knox J, et al. Relationship between quantitative estrogen and progesterone receptor expression and human epidermal growth factor receptor 2 (HER-2) status with recurrence in the Arimidex, Tamoxifen, Alone or in Combination trial. J Clin Oncol. Mar. 1. 2008;26(7):1059-65. Not eligible target population. [pmid: 18227529].
688 Dowsett M, Cuzick J, Howell A, et al. Pharmacokinetics of anastrozole and tamoxifen alone, and in combination, during adjuvant endocrine therapy for early breast cancer in postmenopausal women: a sub-protocol of the ‘Arimidex and tamoxifen alone or in combination’ (ATAC) trial. Br J Cancer. Aug. 3. 2001;85(3):317-24. Not eligible target population. [pmid: 11487258].
689 Dowsett M, Ebbs SR, Dixon JM, et al. Biomarker changes during neoadjuvant anastrozole, tamoxifen, or the combination: influence of hormonal status and HER-2 in breast cancer--a study from the IMPACT trialists. J Clin Oncol. Apr. 10. 2005;23(11):2477-92. Not eligible target population. [pmid: 15767642].
690 Dowsett M, Jones A, Johnston SR, et al. In vivo measurement of aromatase inhibition by letrozole (CGS 20267) in postmenopausal patients with breast cancer. Clin Cancer Res. Dec. 1995;1(12):1511-5. Not eligible target population. [pmid: 9815951].
691 Dowsett M, Mehta A, King N, et al. An endocrine and pharmacokinetic study of four oral doses of formestane in postmenopausal breast cancer patients. Eur J Cancer. 1992;28:2-3. 415. 20. Not eligible target population. [pmid: 1567667].
692 Dowsett M, Murray RM, Pitt P, et al. Antagonism of aminoglutethimide and danazol in the suppression of serum free oestradiol in breast cancer patients. Eur J Cancer Clin Oncol. Sep. 1985;21(9):1063-8. Not eligible target population. [pmid: 4065179].
693 Dowsett M, Smith IE, Ebbs SR, et al. Short-term changes in Ki-67 during neoadjuvant treatment of primary breast cancer with anastrozole or tamoxifen alone or combined correlate with recurrence-free survival. Clin Cancer Res. Jan. 15. 2005;11(2 Pt 2):951s-8s. Not eligible target population. [pmid: 15701892].
694 Dowsett M, Tobias JS, Howell A, et al. The effect of anastrozole on the pharmacokinetics of tamoxifen in post-menopausal women with early breast cancer. Br J Cancer. Jan. 1999;79(2):311-5. Not eligible target population. [pmid: 9888474].
695 Doyle EM, Banville N, Quinn CM, et al. Radial scars/complex sclerosing lesions and malignancy in a screening programme: incidence and histological features revisited. Histopathology. Apr. 2007;50(5):607-14. Not eligible level of evidence. [pmid: 17394497].
696 Doyle JM, O’Doherty A, Coffey L, et al. Can the radiologist accurately predict the adequacy of sampling when performing ultrasound-guided core biopsy of BI-RADS category 4 and 5 lesions detected on screening mammography. Clin Radiol. Sep. 2005;60(9):999-1005. Not eligible outcomes. [pmid: 16124982].
697 Doyle T, Schultz DJ, Peters C, et al. Long-term results of local recurrence after breast conservation treatment for invasive breast cancer. Int J Radiat Oncol Biol Phys. Sep. 1. 2001;51(1):74-80. Not eligible target population. [pmid: 11516854].
698 Dragun AE, Harper JL, Jenrette JM, et al. Predictors of cosmetic outcome following MammoSite breast brachytherapy: a single-institution experience of 100 patients with two years of follow-up. Int J Radiat Oncol Biol Phys. Jun. 1. 2007;68(2):354-8. Not eligible target population. [pmid: 17383829].
699 Drew PJ, Chatterjee S, Turnbull LW, et al. Dynamic contrast enhanced magnetic resonance imaging of the breast is superior to triple assessment for the pre-operative detection of multifocal breast cancer. Ann Surg Oncol. Sep. 1999;6(6):599-603. Not eligible target population. [pmid: 10493630].
700 du Toit RS, Locker AP, Ellis IO, et al. An evaluation of differences in prognosis, recurrence patterns and receptor status between invasive lobular and other invasive carcinomas of the breast. Eur J Surg Oncol. Jun. 1991;17(3):251-7. Not eligible target population. [pmid: 1646127].
701 Duarte GM, dos Santos CC, Torresan RZ, et al. Radioguided surgery using intravenous 99mTc sestamibi associated with breast magnetic resonance imaging for guidance of breast cancer resection. Breast J. May–Jun. 2006;12(3):202-7. Not eligible target population. [pmid: 16684316].
702 Dublin E, Hanby A, Patel NK, et al. Immunohistochemical expression of uPA, uPAR, and PAI-1 in breast carcinoma. Fibroblastic expression has strong associations with tumor pathology. Am J Pathol. Oct. 2000;157(4):1219-27. Not eligible outcomes. [pmid: 11021826].
703 Dublin EA, Barnes DM, Wang DY, et al. TGF alpha and TGF beta expression in mammary carcinoma. J Pathol. May. 1993;170(1):15-22. Not eligible outcomes. [pmid: 8392105].
704 Duchesne N, Parker SH, Lechner MC, et al. Multicenter evaluation of a new ultrasound-guided biopsy device: Improved ergonomics, sampling and rebiopsy rates. Breast J. Jan–Feb. 2007;13(1):36-43. Not eligible outcomes. [pmid: 17214791].
705 Duffy S, Jackson TL, Lansdown M, et al. The ATAC (‘Arimidex’, Tamoxifen, Alone or in Combination) adjuvant breast cancer trial: first results of the endometrial sub-protocol following 2 years of treatment. Hum Reprod. Feb. 2006;21(2):545-53. Not eligible target population. [pmid: 16210385].
706 Duffy S, Jackson TL, Lansdown M, et al. The ATAC adjuvant breast cancer trial in postmenopausal women: baseline endometrial subprotocol data. BJOG. Dec. 2003;110(12):1099-106. Not eligible target population. [pmid: 14664881].
707 Duffy SR, Taylor L. Molecular markers in the endometrium at baseline of postmenopausal patients with early breast cancer in the ATAC (Arimidex, tamoxifen, alone, or in combination) trial. Am J Obstet Gynecol. Dec. 2004;191(6):1921-7. Not eligible target population. [pmid: 15592273].
708 Duffy SW, Tabar L, Vitak B, et al. The relative contributions of screen-detected in situ and invasive breast carcinomas in reducing mortality from the disease. Eur J Cancer. Aug. 2003;39(12):1755-60. Secondary data analysis. [pmid: 12888371].
709 Dugan T, Balsara G, Dunton CJ, et al. Cutaneous involvement by an ovarian serous tumor of low malignant potential. Acta Obstet Gynecol Scand. 1991;70:7-8. 625. 8. Case Reports.
710 Dulaimi E, Hillinck J, Ibanez de Caceres I, et al. Tumor suppressor gene promoter hypermethylation in serum of breast cancer patients. Clin Cancer Res. Sep. 15. 2004;10(18 Pt 1):6189-93. Not eligible outcomes. [pmid: 15448006].
711 Dunphy FR 2nd, Spitzer G. Long-term complete remission of stage IV breast cancer after high-dose chemotherapy and autologous bone marrow transplantation. Am J Clin Oncol. Aug. 1990;13(4):364-6. Case Reports. [pmid: 2165740].
712 Dupont EL, Kuhn MA, McCann C, et al. The role of sentinel lymph node biopsy in women undergoing prophylactic mastectomy. Am J Surg. Oct. 2000;180(4):274-7. Not eligible target population. [pmid: 11113434].
713 Dupont WD, Page DL. Relative risk of breast cancer varies with time since diagnosis of atypical hyperplasia. Human Pathology. 1989;20(8):723-5. Not eligible outcomes. [pmid: 2744746].
714 Dutrillaux B, Gerbault-Seureau M, Remvikos Y, et al. Breast cancer genetic evolution: I. Data from cytogenetics and DNA content. Breast Cancer Res Treat. Nov. 1991;19(3):245-55. Not eligible outcomes. [pmid: 1663804].
715 Dzierzanowski M, Melville KA, Barnes PJ, et al. Ductal carcinoma in situ in core biopsies containing invasive breast cancer: correlation with extensive intraductal component and lumpectomy margins. J Surg Oncol. May. 1. 2005;90(2):71-6. Not eligible target population. [pmid: 15844190].
716 Easley S, Abdul-Karim FW, Klein N, et al. Segregation of radiographic calcifications in stereotactic core biopsies of breast: is it necessary. Breast J. Sep–Oct. 2007;13(5):486-9. Not eligible outcomes. [pmid: 17760670].
717 Eberlein TJ, Connolly JL, Schnitt SJ, et al. Predictors of local recurrence following conservative breast surgery and radiation therapy. The influence of tumor size. Arch Surg. Jun. 1990;125(6):771-5. discussion 5-7. Not eligible target population. [pmid: 2161207].
718 Eby PR, Ochsner JE, DeMartini WB, et al. Is surgical excision necessary for focal atypical ductal hyperplasia found at stereotactic vacuum-assisted breast biopsy. Ann Surg Oncol. Nov. 2008;15(11):3232-8. Not eligible outcomes. [pmid: 18696163].
719 Eby PR, Ochsner JE, DeMartini WB, et al. Frequency and upgrade rates of atypical ductal hyperplasia diagnosed at stereotactic vacuum-assisted breast biopsy: 9-versus 11-gauge. AJR American Journal of Roentgenology. 2009;192(1):229-34. Not eligible exposure. [pmid: 19098204].
720 Eccles DM, Pichert G. Familial non-BRCA1/BRCA2-associated breast cancer. Lancet Oncology. 2005;6(9):705-11. Review. [pmid: 16129371].
721 Echevarria JJ, Lopez-Ruiz JA, Martin D, et al. Usefulness of MRI in detecting occult breast cancer associated with Paget’s disease of the nipple-areolar complex. Br J Radiol. Dec. 2004;77(924):1036-9. Not eligible target population. [pmid: 15569646].
722 Edeiken S. Mammography in the symptomatic woman. Cancer. Apr. 1. 1989;63(7):1412-4. Not eligible target population. [pmid: 2537680].
723 Edeiken S, Russo DP, Knecht J, et al. Angiosarcoma after tylectomy and radiation therapy for carcinoma of the breast. Cancer. Aug. 1. 1992;70(3):644-7. Case Reports. [pmid: 1320451].
724 Egense M, Brunner S, Hansen H, et al. Nonpalpable breast cancer: a mammographic-histological correlation. Recent Results Cancer Res. 1990;119:116-21. Not eligible outcomes. [pmid: 2173081].
725 Ehlinger P, Peeters LC, Servais J, et al. Hormonal therapy in the treatment of mandibular metastasis of breast carcinoma. Report of a case. Int J Oral Maxillofac Surg. Apr. 1993;22(2):108-9. Case Reports. [pmid: 8391556].
726 Eichbaum M, Harms W, Bolz S, et al. Generalized lichen ruber planus--induced by radiotherapy of the breast. Onkologie. Nov. 2006;29(11):521-3. Case Reports. [pmid: 17068387].
727 Eiermann W, Paepke S, Appfelstaedt J, et al. Preoperative treatment of postmenopausal breast cancer patients with letrozole: A randomized double-blind multicenter study. Ann Oncol. Nov. 2001;12(11):1527-32. Not eligible target population. [pmid: 11822750].
728 Ekanem VJ, Aligbe JU. Histopathological types of breast cancer in Nigerian women: a 12-year review 1993-2004. Afr J Reprod Health. Apr. 2006;10(1):71-5. Not eligible target population. [pmid: 16999196].
729 Ekeh AP, Alleyne RS, Duncan AO. Role of mammography in diagnosis of breast cancer in an inner-city hospital. J Natl Med Assoc. Aug. 2000;92(8):372-4. Not eligible outcomes. [pmid: 10992681].
730 el Hussein E, Tan SL. Successful in vitro fertilization and embryo transfer after treatment of invasive carcinoma of the breast. Fertil Steril. Jul. 1992;58(1):194-6. Case Reports. [pmid: 1320575].
731 El Khouli RH, Jacobs MA, Bluemke DA. Magnetic resonance imaging of the breast. Semin Roentgenol. Oct. 2008;43(4):265-81. Review. [pmid: 18774031].
732 el Yousef SJ, O’Connell DM. Magnetic resonance imaging of the breast. Magn Reson Annu. 1986:177-95. Not eligible outcomes.
733 el Yousef SJ, O’Connell DM, Duchesneau RH, et al. Benign and malignant breast disease: magnetic resonance and radiofrequency pulse sequences. AJR Am J Roentgenol. Jul. 1985;145(1):1-8. Not eligible outcomes. [pmid: 2988320].
734 Eliat PA, Dedieu V, Bertino C, et al. Magnetic resonance imaging contrast-enhanced relaxometry of breast tumors: an MRI multicenter investigation concerning 100 patients. Magn Reson Imaging. May. 2004;22(4):475-81. Not eligible outcomes. [pmid: 15120166].
735 Ellis IO, Bell J, Ronan JE, et al. Immunocytochemical investigation of intermediate filament proteins and epithelial membrane antigen in spindle cell tumours of the breast. J Pathol. Feb. 1988;154(2):157-65. Not eligible outcomes. [pmid: 2450980].
736 Ellis IO, Coleman D, Wells C, et al. Impact of a national external quality assessment scheme for breast pathology in the UK. J Clin Pathol. Feb. 2006;59(2):138-45. Not eligible outcomes. [pmid: 16443727].
737 Ellis MJ, Ma C. Letrozole in the neoadjuvant setting: the P024 trial. Breast Cancer Res Treat. 2007;105(Suppl 1):33-43. Not eligible target population. [pmid: 17912634].
738 Ellis PE, Fong LF, Rolfe KJ, et al. The role of p53 and Ki67 in Paget’s disease of the vulva and the breast. Gynecol Oncol. Aug. 2002;86(2):150-6. Not eligible target population. [pmid: 12144821].
739 Ellsworth DL, Ellsworth RE, Liebman MN, et al. Genomic instability in histologically normal breast tissues: implications for carcinogenesis. Lancet Oncology. 2004;5(12):753-8. Review. [pmid: 15581548].
740 Elmore JG, Nakano CY, Koepsell TD, et al. International variation in screening mammography interpretations in community-based programs. J Natl Cancer Inst. Sep. 17. 2003;95(18):1384-93. Not eligible target population. [pmid: 13130114].
741 El-Sayed ME, Rakha EA, Reed J, et al. Predictive value of needle core biopsy diagnoses of lesions of uncertain malignant potential (B3) in abnormalities detected by mammographic screening. Histopathology. Dec. 2008;53(6):650-7. Not eligible outcomes. [pmid: 19076681].
742 el-Sharkawi A, Waters JS. The place for conservative treatment in the management of Paget’s disease of the nipple. Eur J Surg Oncol. Jun. 1992;18(3):301-3. Case Reports. [pmid: 1318852].
743 Elsheikh TM, Silverman JF. Follow-up surgical excision is indicated when breast core needle biopsies show atypical lobular hyperplasia or lobular carcinoma in situ: a correlative study of 33 patients with review of the literature. Am J Surg Pathol. Apr. 2005;29(4):534-43. Not eligible outcomes. [pmid: 15767810].
744 Elson CE, Kufe D, Johnston WW. Immunohistochemical detection and significance of axillary lymph node micrometastases in breast carcinoma. A study of 97 cases. Anal Quant Cytol Histol. Jun. 1993;15(3):171-8. Not eligible target population. [pmid: 7688511].
745 Elston CW. Pathological aspects of the UK Breast Screening Project with special reference to minimal and ‘borderline’ lesions. Aust N Z J Surg. Jun. 1984;54(3):201-4. Not eligible outcomes. [pmid: 6590015].
746 Eltahir A, Jibril JA, Squair J, et al. The accuracy of “one-stop” diagnosis for 1,110 patients presenting to a symptomatic breast clinic. J R Coll Surg Edinb. Aug. 1999;44(4):226-30. Not eligible outcomes. [pmid: 10453144].
747 El-Tamer M, Axiotis C, Kim E, et al. Accurate prediction of the amount of in situ tumor in palpable breast cancers by core needle biopsy: implications for neoadjuvant therapy. Ann Surg Oncol. Jul–Aug. 1999;6(5):461-6. Not eligible outcomes. [pmid: 10458684].
748 El-Tamer M, Chun J, Gill M, et al. Incidence and clinical significance of lymph node metastasis detected by cytokeratin immunohistochemical staining in ductal carcinoma in situ. Ann Surg Oncol. Mar. 2005;12(3):254-9. Not eligible exposure. [pmid: 15827818].
749 Ely KA, Carter BA, Jensen RA, et al. Core biopsy of the breast with atypical ductal hyperplasia: a probabilistic approach to reporting. Am J Surg Pathol. Aug. 2001;25(8):1017-21. Not eligible outcomes. [pmid: 11474285].
750 Emanuel PO, de Vinck D, Waldorf HA, et al. Recurrent endocrine mucin-producing sweat gland carcinoma. Ann Diagn Pathol. Dec. 2007;11(6):448-52. Case Reports. [pmid: 18022131].
751 Emberley ED, Niu Y, Njue C, et al. Psoriasin (S100A7) expression is associated with poor outcome in estrogen receptor-negative invasive breast cancer. Clin Cancer Res. Jul. 2003;9(7):2627-31. Not eligible target population. [pmid: 12855640].
752 England DW, Chan SY, Stonelake PS, et al. Assessment of excision margins following wide local excision for breast carcinoma using specimen scrape cytology and tumour bed biopsy. Eur J Surg Oncol. Aug. 1994;20(4):425-9. Not eligible outcomes. [pmid: 8076703].
753 Erkus M, Meteoglu I, Culhaci N, et al. Does thymidine phosphorylase correlate with angiogenesis in intraductal carcinoma of the breast. Saudi Med J. Sep. 2006;27(9):1329-33. Not eligible outcomes. [pmid: 16951768].
754 Erlandson RA, Carstens PH. Ultrastructure of tubular carcinoma of the breast. Cancer. Apr. 1972;29(4):987-95. Not eligible outcomes. [pmid: 4335981].
755 Escobar PF, Patrick R, Rybicki L, et al. Primary gynecological neoplasms and clinical outcomes in patients diagnosed with breast carcinoma. Int J Gynecol Cancer. Jan–Feb. 2006;16(Suppl 1):118-22. Not eligible target population. [pmid: 16515578].
756 Eskelinen M, Lipponen P, Marin S, et al. Prognostic factors in human pancreatic cancer, with special reference to quantitative histology. Scand J Gastroenterol. May. 1991;26(5):483-90. Not eligible target population. [pmid: 1651557].
757 Esposito NN, Dabbs DJ, Bhargava R. Are encapsulated papillary carcinomas of the breast in situ or invasive? A basement membrane study of 27 cases. Am J Clin Pathol. Feb. 2009;131(2):228-42. Not eligible outcomes. [pmid: 19141383].
758 Esserman L, Hylton N, Yassa L, et al. Utility of magnetic resonance imaging in the management of breast cancer: evidence for improved preoperative staging. J Clin Oncol. Jan. 1999;17(1):110-9. Not eligible level of evidence. [pmid: 10458224].
759 Esserman LJ, Kumar AS, Herrera AF, et al. Magnetic resonance imaging captures the biology of ductal carcinoma in situ. J Clin Oncol. Oct. 1. 2006;24(28):4603-10. Not eligible level of evidence. [pmid: 17008702].
760 Esslimani-Sahla M, Kramar A, Simony-Lafontaine J, et al. Increased estrogen receptor betacx expression during mammary carcinogenesis. Clin Cancer Res. May. 1. 2005;11(9):3170-4. Not eligible outcomes. [pmid: 15867209].
761 Estilo CL, Fornier M, Farooki A, et al. Osteonecrosis of the jaw related to bevacizumab. J Clin Oncol. Aug. 20. 2008;26(24):4037-8. Case Reports. [pmid: 18711196].
762 Eusebi V, Feudale E, Foschini MP, et al. Long-term follow-up of in situ carcinoma of the breast. Semin Diagn Pathol. Aug. 1994;11(3):223-35. Not eligible level of evidence. [pmid: 7831534].
763 Evans A, Clements K, Maxwell A, et al. Mammographic bi-dimensional product: a powerful predictor of successful excision of ductal carcinoma in situ. Clin Radiol. Aug. 2007;62(8):787-91. Not eligible outcomes. [pmid: 17604769].
764 Evans AJ, Wilson AR, Burrell HC, et al. Mammographic features of ductal carcinoma in situ (DCIS) present on previous mammography. Clin Radiol. Oct. 1999;54(10):644-6. Not eligible outcomes. [pmid: 10541387].
765 Evans SB, Kaufman SA, Price LL, et al. Persistent seroma after intraoperative placement of MammoSite for accelerated partial breast irradiation: incidence, pathologic anatomy, and contributing factors. Int J Radiat Oncol Biol Phys. Jun. 1. 2006;65(2):333-9. Not eligible target population. [pmid: 16545918].
766 Everson RB, Li FP, Fraumeni JF Jr, et al. Familial male breast cancer. Lancet. Jan. 3. 1976;1(7949):9-12. Case Reports. [pmid: 54567].
767 Fabian CJ, Kimler BF, Anderson J, et al. Breast cancer chemoprevention phase I evaluation of biomarker modulation by arzoxifene, a third generation selective estrogen receptor modulator. Clin Cancer Res. Aug. 15. 2004;10(16):5403-17. Not eligible outcomes. [pmid: 15328178].
768 Fabian CJ, Kimler BF, Zalles CM, et al. Short-term breast cancer prediction by random periareolar fine-needle aspiration cytology and the Gail risk model. J Natl Cancer Inst. Aug. 2. 2000;92(15):1217-27. Not eligible outcomes. [pmid: 10922407].
769 Fabian CJ, Zalles C, Kamel S, et al. Breast cytology and biomarkers obtained by random fine needle aspiration: use in risk assessment and early chemoprevention trials. J Cell Biochem Suppl. 1997:28-29. 101. 10. Not eligible level of evidence.
770 Fabre A, Fournier A, Mesrine S, et al. Progestagens use before menopause and breast cancer risk according to histology and hormone receptors. Cancer Epidemiol Biomarkers Prev. Oct. 2008;17(10):2723-8. Not eligible outcomes. [pmid: 18843015].
771 Facius M, Renz DM, Neubauer H, et al. Characteristics of ductal carcinoma in situ in magnetic resonance imaging. Clin Imaging. Nov–Dec. 2007;31(6):394-400. Not eligible level of evidence. [pmid: 17996602].
772 Fadare O, Dadmanesh F, Alvarado-Cabrero I, et al. Lobular intraepithelial neoplasia [lobular carcinoma in situ] with comedo-type necrosis: A clinicopathologic study of 18 cases. Am J Surg Pathol. Nov. 2006;30(11):1445-53. Not eligible target population. [pmid: 17063087].
773 Fagerlin A, Lakhani I, Lantz PM, et al. An informed decision? Breast cancer patients and their knowledge about treatment. Patient Educ Couns. Dec. 1. 2006:64-3. 303. 12. Not eligible outcomes.
774 Fahy BN, Bold RJ, Schneider PD, et al. Cost-benefit analysis of biopsy methods for suspicious mammographic lesions; discussion 994-5. Arch Surg. Sep. 2001;136(9):990-4. Not eligible outcomes. [pmid: 11529819].
775 Fajardo LL, Pisano ED, Caudry DJ, et al. Stereotactic and sonographic large-core biopsy of nonpalpable breast lesions: results of the Radiologic Diagnostic Oncology Group V study. Acad Radiol. Mar. 2004;11(3):293-308. Not eligible outcomes. [pmid: 15035520].
776 Farnie G, Clarke RB, Spence K, et al. Novel cell culture technique for primary ductal carcinoma in situ: role of Notch and epidermal growth factor receptor signaling pathways. J Natl Cancer Inst. Apr. 18. 2007;99(8):616-27. Not eligible level of evidence. [pmid: 17440163].
777 Farshid G, Downey P, Gill PG. Atypical presentations of screen-detected DCIS Implications for pre-operative assessment and surgical intervention. Breast. Apr. 2007;16(2):161-71. Not eligible outcomes. [pmid: 17097878].
778 Farshid G, Moinfar F, Meredith DJ, et al. Spindle cell ductal carcinoma in situ. An unusual variant of ductal intra-epithelial neoplasia that simulates ductal hyperplasia or a myoepithelial proliferation. Virchows Arch. Jul. 2001;439(1):70-7. Not eligible level of evidence. [pmid: 11499843].
779 Farshid G, Pieterse S. Core imprint cytology of screen-detected breast lesions is predictive of the histologic results. Cancer. Jun. 25. 2006;108(3):150-6. Not eligible outcomes. [pmid: 16634070].
780 Farshid G, Pieterse S, King JM, et al. Mucocele-like lesions of the breast: a benign cause for indeterminate or suspicious mammographic microcalcifications. Breast J. Jan–Feb. 2005;11(1):15-22. Not eligible outcomes. [pmid: 15647073].
781 Farshid G, Rush G. Assessment of 142 stellate lesions with imaging features suggestive of radial scar discovered during population-based screening for breast cancer. Am J Surg Pathol. Dec. 2004;28(12):1626-31. Not eligible outcomes. [pmid: 15577683].
782 Faupel-Badger JM, Prindiville SA, Venzon D, et al. Effects of raloxifene on circulating prolactin and estradiol levels in premenopausal women at high risk for developing breast cancer. Cancer Epidemiol Biomarkers Prev. Jun. 2006;15(6):1153-8. Not eligible outcomes. [pmid: 16775175].
783 Faverly DR, Hendriks JH, Holland R. Breast carcinomas of limited extent: frequency, radiologic-pathologic characteristics, and surgical margin requirements. Cancer. Feb. 15. 2001;91(4):647-59. Not eligible target population. [pmid: 11241230].
784 Fayanju OM, Ritter J, Gillanders WE, et al. Therapeutic management of intracystic papillary carcinoma of the breast: the roles of radiation and endocrine therapy. Am J Surg. Oct. 2007;194(4):497-500. Not eligible target population. [pmid: 17826064].
785 Fedorcik GG, Sachs R, Goldfarb MA. Oncologic and aesthetic results following breast-conserving therapy with 0.5 cm margins in 100 consecutive patients. Breast J. May–Jun. 2006;12(3):208-11. Not eligible outcomes. [pmid: 16684317].
786 Fein DA, Fowble BL, Hanlon AL, et al. Does the placement of surgical clips within the excision cavity influence local control for patients treated with breast-conserving surgery and irradiation. Int J Radiat Oncol Biol Phys. Mar. 15. 1996;34(5):1009-17. Not eligible target population. [pmid: 8600083].
787 Feller WF, Holt R, Spear S, et al. Modified radical mastectomy with immediate breast reconstruction. Am Surg. Mar. 1986;52(3):129-33. Not eligible level of evidence. [pmid: 3006563].
788 Fentiman I. Ductal carcinoma in situ of the breast. Practitioner. May. 1992;236(1514):502-4. 7. Secondary data analysis. [pmid: 1333595].
789 Fentiman IS. The problem of ductal carcinoma in situ of the breast. Ann Chir Gynaecol. 1992;81(4):334-6. No primary data. [pmid: 1336650].
790 Fentiman IS, Julien JP, van Dongen JA, et al. Reasons for non-entry of patients with DCIS of the breast into a randomised trial (EORTC 10853). Eur J Cancer. 1991;27(4):450-2. Not eligible outcomes. [pmid: 1851620].
791 Fenton JJ, Taplin SH, Carney PA, et al. Influence of computer-aided detection on performance of screening mammography. N Engl J Med. Apr. 5. 2007;356(14):1399-409. Not eligible outcomes. [pmid: 17409321].
792 Ferguson CM, Powell RW. Breast masses in young women. Arch Surg. Nov. 1989;124(11):1338-41. Not eligible target population. [pmid: 2554849].
793 Ferguson DJ, Anderson TJ. Distribution of dense core granules in normal, benign and malignant breast tissue. J Pathol. Sep. 1985;147(1):59-65. Not eligible outcomes. [pmid: 2995627].
794 Ferguson JE, Schor AM, Howell A, et al. Tenascin distribution in the normal human breast is altered during the menstrual cycle and in carcinoma. Differentiation. Feb. 1990;42(3):199-207. Not eligible outcomes. [pmid: 1692795].
795 Fernandes FJ, Costa MM, Bernardo M. Rarities in breast pathology. Bilateral Paget’s disease of the breast--a case report. Eur J Surg Oncol. Apr. 1990;16(2):172-4. Not eligible target population. [pmid: 2157609].
796 Fernandez-Aguilar S, Simon P, Buxant F, et al. Tubular carcinoma of the breast and associated intra-epithelial lesions: a comparative study with invasive low-grade ductal carcinomas. Virchows Arch. Oct. 2005;447(4):683-7. Not eligible target population. [pmid: 16091953].
797 Fernandez-Flores A. Toker cell related to the folliculo-sebaceous-apocrine unit: a study of horizontal sections of the nipple. Rom J Morphol Embryol. 2008;49(3):339-43. Not eligible outcomes. [pmid: 18758638].
798 Fernandez-Madrid F, Tang N, Alansari H, et al. Autoantibodies to Annexin XI-A and Other Autoantigens in the Diagnosis of Breast Cancer. Cancer Res. Aug. 1. 2004;64(15):5089-96. Not eligible outcomes. [pmid: 15289310].
799 Fernandopulle SM, Cher-Siangang P, Tan PH. Breast carcinoma in women 35 years and younger: a pathological study. Pathology. Jun. 2006;38(3):219-22. Not eligible outcomes. [pmid: 16753742].
800 Ferrari L, Zilembo N, Bajetta E, et al. Effect of two-4-hydroxyandrostenedione doses on serum insulin-like growth factor I levels in advanced breast cancer. Breast Cancer Res Treat. 1994;30(2):127-32. Not eligible target population. [pmid: 7949210].
801 Ferreira M, Albarracin CT, Resetkova E. Pseudoangiomatous stromal hyperplasia tumor: a clinical, radiologic and pathologic study of 26 cases. Mod Pathol. Feb. 2008;21(2):201-7. Not eligible target population. [pmid: 18084246].
802 Ferreiro JA, Gisvold JJ, Bostwick DG. Accuracy of frozen-section diagnosis of mammographically directed breast biopsies. Results of 1,490 consecutive cases. Am J Surg Pathol. Nov. 1995;19(11):1267-71. Not eligible outcomes. [pmid: 7573688].
803 Fetissof F, Dubois MP, Arbeille-Brassart B, et al. Argyrophilic cells in mammary carcinoma. Hum Pathol. Feb. 1983;14(2):127-34. Not eligible outcomes. [pmid: 6299922].
804 Fex G, Linell F, Ljungberg O. Cellular retinol-binding protein in normal and neoplastic human mammary gland. Breast Cancer Res Treat. 1985;6(2):131-6. Not eligible outcomes. [pmid: 2996666].
805 Field LR, Wilson TE, Strawderman M, et al. Mammographic screening in women more than 64 years old: a comparison of 1- and 2-year intervals. AJR Am J Roentgenol. Apr. 1998;170(4):961-5. Not eligible outcomes. [pmid: 9530044].
806 Finkelstein SD, Sayegh R, Thompson WR. Late recurrence of ductal carcinoma in situ at the cutaneous end of surgical drainage following total mastectomy. Am Surg. Jul. 1993;59(7):410-4. Case Reports. [pmid: 8391769].
807 Finkenstedt G, Hofle G, Pallua A, et al. Changes in the volume of residual pituitary adenomas in patients with adult-onset growth hormone deficiency during replacement therapy with the recombinant human growth hormone. Wien Klin Wochenschr. Nov. 12. 1999;111(21):887-90. Not eligible target population. [pmid: 10599151].
808 Fisher B, Bryant J, Dignam JJ, et al. Tamoxifen, radiation therapy, or both for prevention of ipsilateral breast tumor recurrence after lumpectomy in women with invasive breast cancers of one centimeter or less. J Clin Oncol. Oct. 15. 2002;20(20):4141-9. Not eligible target population. [pmid: 12377957].
809 Fisher ER, Costantino J, Fisher B, et al. Pathologic findings from the National Surgical Adjuvant Breast Project (NSABP) Protocol B-17. Five-year observations concerning lobular carcinoma in situ. Cancer. Oct. 1. 1996;78(7):1403-16. Not eligible target population. [pmid: 8839545].
810 Fisher ER, Leeming R, Anderson S, et al. Conservative management of intraductal carcinoma (DCIS) of the breast. Collaborating NSABP investigators. J Surg Oncol. Jul. 1991;47(3):139-47. Not eligible level of evidence. [pmid: 1649353].
811 Fisher ER, Posada H, Ramos H. Evaluation of mammography based upon correlation of specimen mammograms and histopathologic findings. Am J Clin Pathol. Jul. 1974;62(1):60-72. Not eligible outcomes. [pmid: 4365737].
812 Fisher ER, Sass R, Fisher B, et al. Pathologic findings from the National Surgical Adjuvant Breast Project (protocol 6). I. Intraductal carcinoma (DCIS). Cancer. Jan. 15. 1986;57(2):197-208. Not eligible level of evidence. [pmid: 3002577].
813 Fisher ER, Siderits R. Value of cytometric analysis for distinction of intraductal carcinoma of the breast. Breast Cancer Res Treat. 1992;21(3):165-72. Not eligible outcomes. [pmid: 1325216].
814 Fisher ER, Taylor M. Changing pattern of some pathologic parameters of mammary carcinoma. Cancer. Dec. 1973;32(6):1380-4. Not eligible outcomes. [pmid: 4357076].
815 Fitzgerald AJ, Wallace VP, Jimenez-Linan M, et al. Terahertz pulsed imaging of human breast tumors. Radiology. May. 2006;239(2):533-40. Not eligible outcomes. [pmid: 16543586].
816 Fitzgibbons PL. Atypical lobular hyperplasia of the breast: a study of pathologists’ responses in the College of American Pathologists Performance Improvement Program in Surgical Pathology. Arch Pathol Lab Med. Mar. 2000;124(3):463-4. Case Reports. [pmid: 10705409].
817 Fitz-Henley M. Images and diagnoses. Patient 1: Paget’s disease. Patient 2: nipple eczma. West Indian Med J. Jun. 32. 2002;51(2):122-3. Not eligible target population. [pmid: 12232935].
818 Fleming FJ, Hill AD, Mc Dermott EW, et al. Intraoperative margin assessment and re-excision rate in breast conserving surgery. Eur J Surg Oncol. Apr. 2004;30(3):233-7. Not eligible target population. [pmid: 15028301].
819 Flieder A, Koerner FC, Pilch BZ, et al. Endocrine mucin-producing sweat gland carcinoma: a cutaneous neoplasm analogous to solid papillary carcinoma of breast. Am J Surg Pathol. Dec. 1997;21(12):1501-6. Case Reports. [pmid: 9414195].
820 Floery D, Helbich TH, Riedl CC, et al. Characterization of benign and malignant breast lesions with computed tomography laser mammography (CTLM): initial experience. Invest Radiol. Jun. 2005;40(6):328-35. Not eligible outcomes. [pmid: 15905718].
821 Florentine BD, Kirsch D, Carroll-Johnson RM, et al. Conservative excision of wire-bracketed breast carcinomas: a community hospital’s experience. Breast J. Sep–Oct. 2004;10(5):398-404. Not eligible outcomes. [pmid: 15327492].
822 Fobben ES, Rubin CZ, Kalisher L, et al. Breast MR imaging with commercially available techniques: radiologic-pathologic correlation. Radiology. Jul. 1995;196(1):143-52. Not eligible outcomes. [pmid: 7784558].
823 Fondrinier E, Muratet JP, Anglade E, et al. Clinical experience with 99mTc-MIBI scintimammography in patients with breast microcalcifications. Breast. Aug. 2004;13(4):316-20. Not eligible outcomes. [pmid: 15325666].
824 Foo ML, Gunderson LL, Nagorney DM, et al. Patterns of failure in grossly resected pancreatic ductal adenocarcinoma treated with adjuvant irradiation +/− 5 fluorouracil. Int J Radiat Oncol Biol Phys. Jun. 15. 1993;26(3):483-9. Not eligible target population. [pmid: 8390422].
825 Forbes JF. The use of early adjuvant aromatase inhibitor therapy: contributions from the BIG 1-98 letrozole trial. Semin Oncol. Apr. 2006;33(2 Suppl 7):S2-7. Not eligible target population. [pmid: 16730270].
826 Ford CE, Faedo M, Crouch R, et al. Progression from normal breast pathology to breast cancer is associated with increasing prevalence of mouse mammary tumor virus-like sequences in men and women. Cancer Res. Jul. 15. 2004;64(14):4755-9. Not eligible outcomes. [pmid: 15256443].
827 Fornage BD, Sneige N, Ross MI, et al. Small (< or = 2-cm) breast cancer treated with US-guided radiofrequency ablation: feasibility study. Radiology. Apr. 2004;231(1):215-24. Not eligible target population. [pmid: 14990810].
828 Forouhar FA. Biologic behavior of in situ ductal carcinoma of the breast. Ann Clin Lab Sci. Jul–Sep. 1999;29(3):167-8. Secondary data analysis. [pmid: 10440579].
829 Forrai G, Polgar C, Zana K, et al. The role of STIR MRI sequence in the evaluation of the breast following conservative surgery and radiotherapy. Neoplasma. 2001;48(1):7-11. Not eligible target population. [pmid: 11327541].
830 Forrest AP, Everington D, McDonald CC, et al. The Edinburgh randomized trial of axillary sampling or clearance after mastectomy. Br J Surg. Nov. 1995;82(11):1504-8. Not eligible target population. [pmid: 8535804].
831 Forszpaniak J. MammoSite balloon brachytherapy: errors, pitfalls, and technical issues for a practicing surgeon. Breast J. Sep–Oct. 2006;12(5 Suppl 2):S191-5. Not eligible outcomes. [pmid: 16959000].
832 Foschini MP, Fornelli A, Peterse JL, et al. Microcalcifications in ductal carcinoma in situ of the breast: histochemical and immunohistochemical study. Hum Pathol. Feb. 1996;27(2):178-83. Not eligible outcomes. [pmid: 8617460].
833 Foster MC, Helvie MA, Gregory NE, et al. Lobular carcinoma in situ or atypical lobular hyperplasia at core-needle biopsy: is excisional biopsy necessary. Radiology. Jun. 2004;231(3):813-9. Not eligible target population. [pmid: 15105449].
834 Fountzilas G, Dafni U, Gogas H, et al. Postoperative dose-dense sequential chemotherapy with epirubicin, paclitaxel and CMF in patients with high-risk breast cancer: safety analysis of the Hellenic Cooperative Oncology Group randomized phase III trial HE 10/00. Ann Oncol. May. 2008;19(5):853-60. Not eligible target population. [pmid: 18042835].
835 Fourquet A, Campana F, Vielh P, et al. Paget’s disease of the nipple without detectable breast tumor: conservative management with radiation therapy. Int J Radiat Oncol Biol Phys. Oct. 1987;13(10):1463-5. Not eligible target population. [pmid: 3040645].
836 Fowble B, Hanlon A, Freedman G, et al. Postmenopausal hormone replacement therapy: effect on diagnosis and outcome in early-stage invasive breast cancer treated with conservative surgery and radiation. J Clin Oncol. Jun. 1999;17(6):1680-8. Not eligible target population. [pmid: 10561204].
837 Fowble B, Hanlon AL, Patchefsky A, et al. The presence of proliferative breast disease with atypia does not significantly influence outcome in early-stage invasive breast cancer treated with conservative surgery and radiation. Int J Radiat Oncol Biol Phys. Aug. 1. 1998;42(1):105-15. Not eligible target population. [pmid: 9747827].
838 Fowble B, Solin LJ, Schultz DJ, et al. Breast recurrence following conservative surgery and radiation: patterns of failure, prognosis, and pathologic findings from mastectomy specimens with implications for treatment. Int J Radiat Oncol Biol Phys. Oct. 1990;19(4):833-42. Not eligible target population. [pmid: 2170305].
839 Fowble B, Solin LJ, Schultz DJ, et al. Breast recurrence and survival related to primary tumor location in patients undergoing conservative surgery and radiation for early-stage breast cancer. Int J Radiat Oncol Biol Phys. 1992;23(5):933-9. Not eligible target population. [pmid: 1322386].
840 Fowble BL, Solin LJ, Schultz DJ, et al. Ten year results of conservative surgery and irradiation for stage I and II breast cancer. Int J Radiat Oncol Biol Phys. Jul. 1991;21(2):269-77. Not eligible target population. [pmid: 1648040].
841 Fox LP, Grossman ME. Images in clinical medicine. Paget’s disease of the breast. N Engl J Med. Jul. 21. 2005;353(3):e3. Not eligible target population. [pmid: 16034005].
842 Franceschi D, Crowe J, Zollinger R, et al. Breast biopsy for calcifications in nonpalpable breast lesions. A prospective study. Arch Surg. Feb. 1990;125(2):170-3. Not eligible outcomes. [pmid: 2154171].
843 Franceschi D, Crowe JP, Lie S, et al. Not all nonpalpable breast cancers are alike. Arch Surg. Aug. 1991;126(8):967-70. discussion 70-1. Not eligible outcomes. [pmid: 1650548].
844 Franceschini G, Masetti R, D’Ugo D, et al. Synchronous bilateral Paget’s disease of the nipple associated with bilateral breast carcinoma. Breast J. Sep–Oct. 2005;11(5):355-6. Case Reports. [pmid: 16174159].
845 Francini G, Petrioli R, Montagnani A, et al. Exemestane after tamoxifen as adjuvant hormonal therapy in postmenopausal women with breast cancer: effects on body composition and lipids. Br J Cancer. Jul. 17. 2006;95(2):153-8. Not eligible target population. [pmid: 16835585].
846 Frank DH, Davis JR, Alberts DS, et al. Nuclear chromatin characteristics of breast solid pattern ductal carcinoma in situ. Anal Quant Cytol Histol. Dec. 2001;23(6):418-26. Not eligible outcomes. [pmid: 11777277].
847 Fraser JL, Raza S, Chorny K, et al. Columnar alteration with prominent apical snouts and secretions: a spectrum of changes frequently present in breast biopsies performed for microcalcifications. Am J Surg Pathol. Dec. 1998;22(12):1521-7. Not eligible outcomes. [pmid: 9850178].
848 Frassoldati A, Guarneri V, Piacentini F, et al. Letrozole versus letrozole plus Lapatinib (GW572016) in hormone-sensitive, HER2-negative operable breast cancer: a double-blind, randomized, phase II study with biomarker evaluation (EGF109077-LAP107692/LETLOB). Clin Breast Cancer. Feb. 2008;8(1):97-100. Not eligible target population. [pmid: 18501066].
849 Freedman GM, Anderson PR, Goldstein LJ, et al. Routine mammography is associated with earlier stage disease and greater eligibility for breast conservation in breast carcinoma patients age 40 years and older. Cancer. Sep. 1. 2003;98(5):918-25. Not eligible outcomes. [pmid: 12942557].
850 Freedman GM, Anderson PR, Goldstein LJ, et al. Four-week course of radiation for breast cancer using hypofractionated intensity modulated radiation therapy with an incorporated boost. Int J Radiat Oncol Biol Phys. Jun. 1. 2007;68(2):347-53. Not eligible target population. [pmid: 17379430].
851 Freedman GM, Anderson PR, Hanlon AL, et al. Pattern of local recurrence after conservative surgery and whole-breast irradiation. Int J Radiat Oncol Biol Phys. Apr. 1. 2005;61(5):1328-36. Not eligible target population. [pmid: 15817334].
852 Frei KA, Bonel HM, Pelte MF, et al. Paget disease of the breast: findings at magnetic resonance imaging and histopathologic correlation. Invest Radiol. Jun. 2005;40(6):363-7. Not eligible target population. [pmid: 15905723].
853 French J, Stirling R, Walsh M, et al. The expression of Ras-GTPase activating protein SH3 domain-binding proteins, G3BPs, in human breast cancers. Histochem J. May. 2002;34(5):223-31. Not eligible target population. [pmid: 12587999].
854 Friedman EP, Hall-Craggs MA, Mumtaz H, et al. Breast MR and the appearance of the normal and abnormal nipple. Clin Radiol. Nov. 1997;52(11):854-61. Not eligible outcomes. [pmid: 9392464].
855 Friedman P, Sanders L, Russo J, et al. Detection and localization of occult lesions using breast magnetic resonance imaging: initial experience in a community hospital. Acad Radiol. Jun. 2005;12(6):728-38. Not eligible outcomes. [pmid: 15935971].
856 Frierson HF Jr. Grade and flow cytometric analysis of ploidy for infiltrating ductal carcinomas. Hum Pathol. Jan. 1993;24(1):24-9. Not eligible outcomes. [pmid: 8380276].
857 Fritzsche FR, Dahl E, Pahl S, et al. Prognostic relevance of AGR2 expression in breast cancer. Clin Cancer Res. Mar. 15. 2006;12(6):1728-34. Not eligible target population. [pmid: 16551856].
858 Fu W, Mittel VK, Young SC. Paget disease of the breast: analysis of 41 patients. Am J Clin Oncol. Aug. 2001;24(4):397-400. Not eligible target population. [pmid: 11474272].
859 Fuckar D, Dekanic A, Stifter S, et al. VEGF expression is associated with negative estrogen receptor status in patients with breast cancer. Int J Surg Pathol. Jan. 2006;14(1):49-55. Not eligible outcomes. [pmid: 16501835].
860 Fuhr JE, Frye A, Kattine AA, et al. Flow cytometric determination of breast tumor heterogeneity. Cancer. Mar. 1. 1991;67(5):1401-5. Not eligible outcomes. [pmid: 1846776].
861 Fujii H, Inagaki M, Kasai S, et al. Genetic progression and heterogeneity in intraductal papillary-mucinous neoplasms of the pancreas. Am J Pathol. Nov. 1997;151(5):1447-54. Not eligible target population. [pmid: 9358771].
862 Fujii K, Fukutomi T, Tsuda H, et al. Microinvasive breast carcinoma with extensive involvement of level III axillary lymph nodes: a case report. Jpn J Clin Oncol. Jan. 1998;28(1):47-9. Case Reports. [pmid: 9491142].
863 Fujita M, Khazenzon NM, Bose S, et al. Overexpression of beta1-chain-containing laminins in capillary basement membranes of human breast cancer and its metastases. Breast Cancer Res. 2005;7(4):R411-21. Not eligible outcomes. [pmid: 15987446].
864 Fujita T, Doihara H, Takabatake D, et al. Multidetector row computed tomography for diagnosing intraductal extension of breast carcinoma. J Surg Oncol. Jul. 1. 2005;91(1):10-6. Not eligible outcomes. [pmid: 15999347].
865 Fukuda M, Nagao K, Nishimura R, et al. Carcinoma arising in fibroadenoma of the breast--a case report and review of the literature. Jpn J Surg. Sep. 1989;19(5):593-6. Case Reports. [pmid: 2593394].
866 Fukunaga M, Ushigome S. Small cell (oat cell) carcinoma of the breast. Pathol Int. Sep. 1998;48(9):744-8. Case Reports. [pmid: 9778114].
867 Fukuoka H, Moriuchi M, Yano H, et al. No association of mouse mammary tumor virus-related retrovirus with Japanese cases of breast cancer. Journal of medical virology. Aug. 2008;80(8):1447-51. Not eligible exposure. [pmid: 18551605].
868 Fukushima N, Walter KM, Uek T, et al. Diagnosing pancreatic cancer using methylation specific PCR analysis of pancreatic juice. Cancer Biol Ther. Jan–Feb. 2003;2(1):78-83. Not eligible target population. [pmid: 12673124].
869 Fukutomi T, Akashi-Tanaka S, Nanasawa T, et al. Multicentricity and histopathological background features of familial breast cancers stratified by menopausal status. Int J Clin Oncol. Apr. 2001;6(2):80-3. Not eligible outcomes. [pmid: 11706754].
870 Fulop JA. Integrative tumor board: recurrent breast cancer or new primary? Naturopathic medicine. Integr Cancer Ther. Sep. 2003;2(3):276-83. Case Reports. [pmid: 15035892].
871 Furman-Haran E, Grobgeld D, Kelcz F, et al. Critical role of spatial resolution in dynamic contrast-enhanced breast MRI. J Magn Reson Imaging. Jun. 2001;13(6):862-7. Not eligible outcomes. [pmid: 11382945].
872 Furusawa H, Namba K, Thomsen S, et al. Magnetic resonance-guided focused ultrasound surgery of breast cancer: reliability and effectiveness. J Am Coll Surg. Jul. 2006;203(1):54-63. Not eligible target population. [pmid: 16798487].
873 Gabka CJ, Maiwald G, Bohmert H. Immediate breast reconstruction for breast carcinoma using the periareolar approach. Plast Reconstr Surg. Apr. 1998;101(5):1228-34. Not eligible outcomes. [pmid: 9529206].
874 Gabriel HA, Feng C, Mendelson EB, et al. Breast MRI for cancer detection in a patient with diabetic mastopathy. AJR Am J Roentgenol. Apr. 2004;182(4):1081-3. Case Reports. [pmid: 15039192].
875 Gadre SA, Perkins GH, Sahin AA, et al. Neovascularization in mucinous ductal carcinoma in situ suggests an alternative pathway for invasion. Histopathology. Nov. 2008;53(5):545-53. Not eligible outcomes. [pmid: 18983463].
876 Gajdos C, Levy M, Herman Z, et al. Complete removal of nonpalpable breast malignancies with a stereotactic percutaneous vacuum-assisted biopsy instrument. J Am Coll Surg. Sep. 1999;189(3):237-40. Not eligible outcomes. [pmid: 10472922].
877 Gajdos C, Tartter PI, Bleiweiss IJ, et al. Mammographic appearance of nonpalpable breast cancer reflects pathologic characteristics. Ann Surg. Feb. 2002;235(2):246-51. Not eligible outcomes. [pmid: 11807365].
878 Galant C, Gala JL, Van Den Berge V, et al. Immunolocalisation of cytochrome P-450 3A enzymes in human breast carcinoma: relationship with tumour differentiation and steroid receptors. Pharmacol Toxicol. Mar. 2001;88(3):142-6. Not eligible outcomes. [pmid: 11245409].
879 Galea MH, Athanassiou E, Bell J, et al. Occult regional lymph node metastases from breast carcinoma: immunohistological detection with antibodies CAM 5.2 and NCRC-11. J Pathol. Nov. 1991;165(3):221-7. Not eligible outcomes. [pmid: 1722247].
880 Galimberti V, Leonardi MC, Rotmensz N, et al. Can axillary and supraclavicular radiotherapy be avoided after breast-conserving surgery and axillary dissection in women with multiple involved axillary nodes? Experience at the European Institute of Oncology. Tumori. Jan–Feb. 2008;94(1):52-8. Not eligible target population. [pmid: 18468335].
881 Gallagher WJ, Koerner FC, Wood WC. Treatment of intraductal carcinoma with limited surgery: long-term follow-up. J Clin Oncol. Mar. 1989;7(3):376-80. Not eligible level of evidence. [pmid: 2537385].
882 Gallicchio LM, Flaws JA, Fowler BA, et al. Metallothionein expression in invasive and in situ breast carcinomas. Cancer Detect Prev. 2005;29(4):332-7. Not eligible outcomes. [pmid: 16122884].
883 Galper S, Blood E, Gelman R, et al. Prognosis after local recurrence after conservative surgery and radiation for early-stage breast cancer. Int J Radiat Oncol Biol Phys. Feb. 1. 2005;61(2):348-57. Not eligible level of evidence. [pmid: 15667952].
884 Galper SR, Lee SJ, Tao ML, et al. Patient preferences for axillary dissection in the management of early-stage breast cancer. J Natl Cancer Inst. Oct. 18. 2000;92(20):1681-7. Not eligible outcomes. [pmid: 11036114].
885 Ganau S, Tortajada L, Rodriguez X, et al. Silicone lymphadenopathy: an unusual cause of internal mammary lymph node enlargement. Breast J. Sep–Oct. 2008;14(5):502-3. Case Reports. [pmid: 18673336].
886 Gandhi A, Holland PA, Knox WF, et al. Evidence of significant apoptosis in poorly differentiated ductal carcinoma in situ of the breast. Br J Cancer. Sep. 1998;78(6):788-94. Not eligible outcomes. [pmid: 9743302].
887 Gandhi A, Holland PA, Knox WF, et al. Effects of a pure antiestrogen on apoptosis and proliferation within human breast ductal carcinoma in situ. Cancer Res. Aug. 1. 2000;60(15):4284-8. Not eligible target population. [pmid: 10945643].
888 Gangopadhyay M, Nijhawan R, Joshi K, et al. Cytology of “significant” breast ductal proliferations. Acta Cytol. Jul–Aug. 1997;41(4):1112-20. Not eligible outcomes. [pmid: 9250308].
889 Gao X, Fisher SG, Emami B. Risk of second primary cancer in the contralateral breast in women treated for early-stage breast cancer: a population-based study. Int J Radiat Oncol Biol Phys. Jul. 15. 2003;56(4):1038-45. Not eligible target population. [pmid: 12829139].
890 Gao Y, Niu Y, Wang X, et al. Genetic changes at specific stages of breast cancer progression detected by comparative genomic hybridization. J Mol Med. Feb. 2009;87(2):145-52. Not eligible outcomes. [pmid: 18936904].
891 Garbay JR, Mathieu MC, Lamuraglia M, et al. Radiofrequency thermal ablation of breast cancer local recurrence: a phase II clinical trial. Ann Surg Oncol. Nov. 2008;15(11):3222-6. Not eligible target population. [pmid: 18709415].
892 Garcia-Giralt E, Ayme Y, Carton M, et al. Second and third line hormonotherapy in advanced post-menopausal breast cancer: a multicenter randomized trial comparing medroxyprogesterone acetate with aminoglutethimide in patients who have become resistant to tamoxifen. Breast Cancer Res Treat. 1992;24(2):139-45. Not eligible target population. [pmid: 8443401].
893 Garijo MF, Val D, Val-Bernal JF. Pagetoid dyskeratosis of the nipple epidermis: an incidental finding mimicking Paget’s disease of the nipple. APMIS. Feb. 2008;116(2):139-46. Not eligible target population. [pmid: 18321365].
894 Garrett PA, Hulka BS, Kim YL, et al. HRAS protooncogene polymorphism and breast cancer. Cancer Epidemiol Biomarkers Prev. Mar–Apr. 1993;2(2):131-8. Not eligible target population. [pmid: 8385520].
895 Gatalica Z. Immunohistochemical analysis of apocrine breast lesions. Consistent over-expression of androgen receptor accompanied by the loss of estrogen and progesterone receptors in apocrine metaplasia and apocrine carcinoma in situ. Pathol Res Pract. 1997;193:11-12. 753. 8. Not eligible target population.
896 Gatek J, Dudesek B, Hnatek L, et al. Local recurrences after conservative surgery in breast carcinoma. Klin Onkol. 2008;21(4):169-73. Language. [pmid: 19102224].
897 Gaudet MM, Britton JA, Kabat GC, et al. Fruits, vegetables, and micronutrients in relation to breast cancer modified by menopause and hormone receptor status. Cancer Epidemiol Biomarkers Prev. Sep. 2004;13(9):1485-94. Not eligible target population. [pmid: 15342450].
898 Gaurav M, Rajgopal S, Mary M, et al. Concomitant tuberculosis and metastasis in axillary lymph nodes: a diagnostic surprise. ANZ J Surg. Sep. 2008;78(9):825-6. Case Reports. [pmid: 18844925].
899 Gauthier ML, Pickering CR, Miller CJ, et al. p38 regulates cyclooxygenase-2 in human mammary epithelial cells and is activated in premalignant tissue. Cancer Res. Mar. 1. 2005;65(5):1792-9. Not eligible outcomes. [pmid: 15753376].
900 Gazet JC, Ford HT, Coombes RC. Randomised trial of chemotherapy versus endocrine therapy in patients presenting with locally advanced breast cancer (a pilot study). Br J Cancer. Feb. 1991;63(2):279-82. Not eligible target population. [pmid: 1825469].
901 Gazet JC, Ford HT, Gray R, et al. Estrogen-receptor-directed neoadjuvant therapy for breast cancer: results of a randomised trial using formestane and methotrexate, mitozantrone and mitomycin C (MMM) chemotherapy. Ann Oncol. May. 2001;12(5):685-91. Not eligible target population. [pmid: 11432629].
902 Gebbia V, Testa A, Valenza R, et al. Levo folinic acid and 5-fluorouracil plus high dose epidoxorubicin as first line treatment for metastatic breast carcinoma. Anticancer Res. Jan–Feb. 1993;13(1):141-4. Not eligible target population. [pmid: 8386492].
903 Geer RJ, Brennan MF. Prognostic indicators for survival after resection of pancreatic adenocarcinoma. Am J Surg. Jan. 1993;165(1):68-72. discussion −3. Not eligible target population. [pmid: 8380315].
904 Geisler J, Haynes B, Anker G, et al. Influence of letrozole and anastrozole on total body aromatization and plasma estrogen levels in postmenopausal breast cancer patients evaluated in a randomized, cross-over study. J Clin Oncol. Feb. 1. 2002;20(3):751-7. Not eligible target population. [pmid: 11821457].
905 Geisler J, King N, Dowsett M, et al. Influence of anastrozole (Arimidex), a selective, non-steroidal aromatase inhibitor, on in vivo aromatisation and plasma oestrogen levels in postmenopausal women with breast cancer. Br J Cancer. Oct. 1996;74(8):1286-91. Not eligible target population. [pmid: 8883419].
906 Geisler J, Lonning PE, Krag LE, et al. Changes in bone and lipid metabolism in postmenopausal women with early breast cancer after terminating 2-year treatment with exemestane: a randomised, placebo-controlled study. Eur J Cancer. Nov. 2006;42(17):2968-75. Not eligible outcomes. [pmid: 16963261].
907 Geisler J, Lundgren S, Berntsen H, et al. Influence of dexaminoglutethimide, an optical isomer of aminoglutethimide, on the disposition of estrone sulfate in postmenopausal breast cancer patients. J Clin Endocrinol Metab. Aug. 1998;83(8):2687-93. Not eligible target population. [pmid: 9709932].
908 Geller BM, Kerlikowske K, Carney PA, et al. Mammography surveillance following breast cancer. Breast Cancer Res Treat. Sep. 2003;81(2):107-15. Not eligible outcomes. [pmid: 14572153].
909 Gennatas CS, Kalovidouris A, Paraskevas GA, et al. A randomized phase II trial of aminoglutethimide and hydrocortisone versus combined aminoglutethimide, hydrocortisone and fluoxymesterone in advanced breast cancer. Radiother Oncol. Jul. 1987;9(3):217-20. Not eligible target population. [pmid: 3628857].
910 Georgian-Smith D, Lawton TJ. Calcifications of lobular carcinoma in situ of the breast: radiologic-pathologic correlation. AJR Am J Roentgenol. May. 2001;176(5):1255-9. Not eligible outcomes. [pmid: 11312190].
911 Gerber B, Krause A, Reimer T, et al. Anastrozole versus tamoxifen treatment in postmenopausal women with endocrine-responsive breast cancer and tamoxifen-induced endometrial pathology. Clin Cancer Res. Feb. 15. 2006;12(4):1245-50. Not eligible target population. [pmid: 16489080].
912 Gershanovich M, Chaudri HA, Campos D, et al. Letrozole, a new oral aromatase inhibitor: randomised trial comparing 2.5 mg daily, 0.5 mg daily and aminoglutethimide in postmenopausal women with advanced breast cancer. Letrozole International Trial Group (AR/BC3). Ann Oncol. Jun. 1998;9(6):639-45. Not eligible target population. [pmid: 9681078].
913 Gershenwald JE, Hunt KK, Kroll SS, et al. Synchronous elective contralateral mastectomy and immediate bilateral breast reconstruction in women with early-stage breast cancer. Ann Surg Oncol. Sep. 1998;5(6):529-38. Not eligible target population. [pmid: 9754762].
914 Gervais A, Leveque J, Bouet-Toussaint F, et al. Dendritic cells are defective in breast cancer patients: a potential role for polyamine in this immunodeficiency. Breast Cancer Res. 2005;7(3):R326-35. Not eligible outcomes. [pmid: 15987427].
915 Ghai S, Muradali D, Bukhanov K, et al. Nonenhancing breast malignancies on MRI: sonographic and pathologic correlation. AJR Am J Roentgenol. Aug. 2005;185(2):481-7. Not eligible target population. [pmid: 16037524].
916 Gherardini G, Thomas R, Basoccu G, et al. Immediate breast reconstruction with the transverse rectus abdominis musculocutaneous flap after skin-sparing mastectomy. Int Surg. Oct–Dec;. 2001;86(4):246-51. Not eligible exposure. [pmid: 12056470].
917 Ghosh S, Sullivan CA, Zerkowski MP, et al. High levels of vascular endothelial growth factor and its receptors (VEGFR-1, VEGFR-2, neuropilin-1) are associated with worse outcome in breast cancer. Hum Pathol. Dec. 2008;39(12):1835-43. Not eligible target population. [pmid: 18715621].
918 Giani C, Campani D, De Negri F, et al. Relationship between progesterone receptor, axillary node status and productive fibrosis in ductal infiltrating carcinoma of the breast. Appl Pathol. 1989;7(4):225-32. Not eligible outcomes. [pmid: 2553078].
919 Giani C, Pinchera A, Breccia M, et al. Relationship between progesterone receptor and productive fibrosis as an index of tumor differentiation in breast cancer. Tumori. Jun. 30. 1988;74(3):287-93. Not eligible outcomes. [pmid: 2840763].
920 Giardina C, Serio G, Lepore G, et al. Pure ductal carcinoma in situ and in situ component of ductal invasive carcinoma of the breast. A preliminary morphometric study. J Exp Clin Cancer Res. Jun. 2003;22(2):279-88. Not eligible outcomes. [pmid: 12866579].
921 Gibbs NM. Comparative study of the histopathology of breast cancer in a screened and unscreened population investigated by mammography. Histopathology. Dec. 1985;9(12):1307-18. Not eligible outcomes. [pmid: 3007322].
922 Gibbs NM. Topographical and histological presentation of mammographic pathology in breast cancer. J Clin Pathol. Jan. 1988;41(1):3-11. Not eligible outcomes. [pmid: 2830318].
923 Gibson GR, Lesnikoski BA, Yoo J, et al. A comparison of ink-directed and traditional whole-cavity re-excision for breast lumpectomy specimens with positive margins. Ann Surg Oncol. Oct. 2001;8(9):693-704. Not eligible level of evidence. [pmid: 11597009].
924 Gierach GL, Lacey JV, Schatzkin A, et al. Nonsteroidal anti-inflammatory drugs and breast cancer risk in the National Institutes of Health AARP Diet and Health Study. Breast Cancer Research : BCR. 2008;10(2):R38-R. Not eligible outcomes. [pmid: 18447943].
925 Giess CS, Keating DM, Osborne MP, et al. Local tumor recurrence following breast-conservation therapy: correlation of histopathologic findings with detection method and mammographic findings. Radiology. Sep. 1999;212(3):829-35. Not eligible level of evidence. [pmid: 10478253].
926 Giles GG, Amos A. Evaluation of the organised mammographic screening programme in Australia. Ann Oncol. Aug. 2003;14(8):1209-11. Not eligible outcomes. [pmid: 12881380].
927 Gill HK, Ioffe OB, Berg WA. When is a diagnosis of sclerosing adenosis acceptable at core biopsy. Radiology. Jul. 2003;228(1):50-7. Not eligible outcomes. [pmid: 12738875].
928 Gilles R, Zafrani B, Guinebretiere JM, et al. Ductal carcinoma in situ: MR imaging-histopathologic correlation. Radiology. Aug. 1995;196(2):415-9. Not eligible outcomes. [pmid: 7617854].
929 Gillett CE, Lee AH, Millis RR, et al. Cyclin D1 and associated proteins in mammary ductal carcinoma in situ and atypical ductal hyperplasia. J Pathol. Apr. 1998;184(4):396-400. Not eligible outcomes. [pmid: 9664905].
930 Gion M, Mione R, Gatti C, et al. Tissue polypeptide antigen in tumor cytosol: a new prognostic indicator in primary breast cancer. Breast Cancer Res Treat. Nov. 1990;17(1):15-21. Not eligible outcomes. [pmid: 1965704].
931 Girling A, Caleffi M, King RJ, et al. Immunohistochemical study of D5 antigen (an oestrogen receptor related protein) in normal breast, benign breast disease, and mammary carcinoma in situ. J Clin Pathol. Apr. 1988;41(4):448-53. Not eligible outcomes. [pmid: 2835402].
932 Giuliano AE, Barth AM, Spivack B, et al. Incidence and predictors of axillary metastasis in T1 carcinoma of the breast. J Am Coll Surg. Sep. 1996;183(3):185-9. Not eligible target population. [pmid: 8784309].
933 Giuseppetti GM, Martegani A, Di Cioccio B, et al. Elastosonography in the diagnosis of the nodular breast lesions: preliminary report. Radiol Med (Torino). Jul–Aug. 2005;110(1-2):69-76. Not eligible outcomes. [pmid: 16163141].
934 Glasziou P, Irwig L. The quality and interpretation of mammographic screening trials for women ages 40-49. J Natl Cancer Inst Monogr. 1997;(22):73-7. Review.
935 Glockner S, Lehmann U, Wilke N, et al. Detection of gene amplification in intraductal and infiltrating breast cancer by laser-assisted microdissection and quantitative real-time PCR. Pathobiology. 2000;68:4-5. 173. 9. Not eligible outcomes.
936 Glockner S, Lehmann U, Wilke N, et al. Amplification of growth regulatory genes in intraductal breast cancer is associated with higher nuclear grade but not with the progression to invasiveness. Lab Invest. Apr. 2001;81(4):565-71. Not eligible outcomes. [pmid: 11304576].
937 Gluck BS, Dershaw DD, Liberman L, et al. Microcalcifications on postoperative mammograms as an indicator of adequacy of tumor excision. Radiology. Aug. 1993;188(2):469-72. Not eligible outcomes. [pmid: 8327699].
938 Gnant MF, Mlineritsch B, Luschin-Ebengreuth G, et al. Zoledronic acid prevents cancer treatment-induced bone loss in premenopausal women receiving adjuvant endocrine therapy for hormone-responsive breast cancer: a report from the Austrian Breast and Colorectal Cancer Study Group. J Clin Oncol. Mar. 1. 2007;25(7):820-8. Not eligible target population. [pmid: 17159195].
939 Gobbi H, Arteaga CL, Jensen RA, et al. Loss of expression of transforming growth factor beta type II receptor correlates with high tumour grade in human breast in-situ and invasive carcinomas. Histopathology. Feb. 2000;36(2):168-77. Not eligible outcomes. [pmid: 10672063].
940 Gobbi H, Jensen RA, Simpson JF, et al. Atypical ductal hyperplasia and ductal carcinoma in situ of the breast associated with perineural invasion. Hum Pathol. Aug. 2001;32(8):785-90. Not eligible outcomes. [pmid: 11521220].
941 Gobbi H, Simpson JF, Jensen RA, et al. Metaplastic spindle cell breast tumors arising within papillomas, complex sclerosing lesions, and nipple adenomas. Mod Pathol. Sep. 2003;16(9):893-901. Not eligible outcomes. [pmid: 13679453].
942 Godfrey PM, Godfrey NV, Fast A, et al. Bilateral brachial plexus palsy after immediate breast reconstruction with TRAM flaps. Plast Reconstr Surg. Apr. 1994;93(5):1078-9. discussion 80-1. Case Reports. [pmid: 8134468].
943 Goel V, Olivotto I, Hislop TG, et al. Patterns of initial management of node-negative breast cancer in two Canadian provinces. British Columbia/Ontario Working Group. CMAJ. Jan. 1. 1997;156(1):25-35. Not eligible outcomes. [pmid: 9006561].
944 Goffin JR, Savage C, Tu D, et al. The difference between study recommendations, stated policy, and actual practice in a clinical trial. Ann Oncol. Aug. 2004;15(8):1267-73. Not eligible target population. [pmid: 15277269].
945 Gold HT, Dick AW. Variations in treatment for ductal carcinoma in situ in elderly women. Med Care. Mar. 2004;42(3):267-75. Not eligible exposure. [pmid: 15076826].
946 Gold HT, Do HT, Dick AW. Correlates and effect of suboptimal radiotherapy in women with ductal carcinoma in situ or early invasive breast cancer. Cancer. Dec. 1. 2008;113(11):3108-15. Not eligible exposure. [pmid: 18932243].
947 Gold JS, Bao L, Ghoussoub RA, et al. Localization and quantitation of expression of the cell motility-related protein thymosin beta15 in human breast tissue. Mod Pathol. Nov. 1997;10(11):1106-12. Not eligible outcomes. [pmid: 9388061].
948 Goldenberg DM, Abdel-Nabi H, Sullivan CL, et al. Carcinoembryonic antigen immunoscintigraphy complements mammography in the diagnosis of breast carcinoma. Cancer. Jul. 1. 2000;89(1):104-15. Not eligible outcomes. [pmid: 10897007].
949 Goldenberg IS, Sedransk N, Volk H, et al. Combined androgen and antimetabolite therapy of advanced female breast cancer. A report of the cooperative breast cancer group. Cancer. Aug. 1975;36(2):308-10. Not eligible target population. [pmid: 1098764].
950 Goldsmith YB, Roistacher N, Baum MS. Capecitabine-induced coronary vasospasm. J Clin Oncol. Aug. 1. 2008;26(22):3802-4. Case Reports. [pmid: 18669470].
951 Goldstein NS, Bassi D, Watts JC, et al. E-cadherin reactivity of 95 noninvasive ductal and lobular lesions of the breast. Implications for the interpretation of problematic lesions. Am J Clin Pathol. Apr. 2001;115(4):534-42. Not eligible outcomes. [pmid: 11293901].
952 Goldstein NS, Kestin LL, Vicini FA. Refined morphologic criteria for tubular carcinoma to retain its favorable outcome status in contemporary breast carcinoma patients. Am J Clin Pathol. Nov. 2004;122(5):728-39. Not eligible outcomes. [pmid: 15491969].
953 Goldstein NS, Lacerna M, Vicini F. Cancerization of lobules and atypical ductal hyperplasia adjacent to ductal carcinoma in situ of the breast. Am J Clin Pathol. Sep. 1998;110(3):357-67. Not eligible level of evidence. [pmid: 9728611].
954 Goldstein NS, Vicini FA, Kestin LL, et al. Differences in the pathologic features of ductal carcinoma in situ of the breast based on patient age. Cancer. Jun. 1. 2000;88(11):2553-60. Not eligible outcomes. [pmid: 10861433].
955 Golinger RC, Gur D, Fisher B, et al. The significance of concordance in mammographic interpretations. Cancer. Oct. 1979;44(4):1252-5. Not eligible outcomes. [pmid: 227558].
956 Gonnelli S, Cadirni A, Caffarelli C, et al. Changes in bone turnover and in bone mass in women with breast cancer switched from tamoxifen to exemestane. Bone. Jan. 2007;40(1):205-10. Not eligible target population. [pmid: 16904960].
957 Gonzalez Gancedo P, ML GC, Ruiz Cacho J, et al. Cathepsin D in breast cancer tissue. Int J Biol Markers. Oct–Dec. 1990;5(4):203-6. Not eligible outcomes. [pmid: 1965545].
958 Gonzalez LO, Corte MD, Junquera S, et al. Expression of androgen receptor and two androgen-induced proteins (apolipoprotein D and pepsinogen C) in ductal carcinoma in situ of the breast. Histopathology. Jun. 2007;50(7):866-74. Not eligible outcomes. [pmid: 17543076].
959 Gonzalez LO, Corte MD, Vazquez J, et al. Study of matrix metalloproteinases and their tissue inhibitors in ductal in situ carcinomas of the breast. Histopathology. Oct. 2008;53(4):403-15. Not eligible outcomes. [pmid: 18983606].
960 Gonzalez RJ, Buzdar AU, Fraser Symmans W, et al. Novel clinical trial designs for treatment of ductal carcinoma in situ of the breast with trastuzumab (herceptin). Breast J. Jan–Feb. 2007;13(1):72-5. No primary data. [pmid: 17214797].
961 Goodman KA, Hong L, Wagman R, et al. Dosimetric analysis of a simplified intensity modulation technique for prone breast radiotherapy. Int J Radiat Oncol Biol Phys. Sep. 1. 2004;60(1):95-102. Not eligible outcomes. [pmid: 15337544].
962 Goodson WH 3rd, Miller TR, Sickles EA, et al. Lack of correlation of clinical breast examination with high-risk histopathology. Am J Med. Dec. 1990;89(6):752-6. Not eligible outcomes. [pmid: 2174645].
963 Gopalan A, Hoda SA. Columnar cell hyperplasia and lobular carcinoma in situ coexisting in the same duct. Breast J. May–Jun. 2005;11(3):210. Case Reports. [pmid: 15871708].
964 Gorski B, Narod SA, Lubinski J. A common missense variant in BRCA2 predisposes to early onset breast cancer. Breast Cancer Res. 2005;7(6):R1023-7. Not eligible outcomes. [pmid: 16280055].
965 Goshtasby P, Mohebi P, Born M. Autologous breast reconstruction with the inchworm flap in an obese woman. Obes Surg. Oct. 2006;16(10):1383-5. Case Reports. [pmid: 17059751].
966 Goss P, Bondarenko IN, Manikhas GN, et al. Phase III, double-blind, controlled trial of atamestane plus toremifene compared with letrozole in postmenopausal women with advanced receptor-positive breast cancer. J Clin Oncol. Nov. 1. 2007;25(31):4961-6. Not eligible target population. [pmid: 17971594].
967 Goss PE. Preventing relapse beyond 5 years: the MA.17 extended adjuvant trial. Semin Oncol. Apr. 2006;33(2 Suppl 7):S8-12. Not eligible target population. [pmid: 16730271].
968 Goss PE. Letrozole in the extended adjuvant setting: MA.17. Breast Cancer Res Treat. 2007;105(Suppl 1):45-53. Not eligible target population. [pmid: 17912635].
969 Goss PE, Hadji P, Subar M, et al. Effects of steroidal and nonsteroidal aromatase inhibitors on markers of bone turnover in healthy postmenopausal women. Breast Cancer Res. 2007;9(4):R52. Not eligible target population. [pmid: 17692126].
970 Goss PE, Ingle JN, Martino S, et al. Randomized trial of letrozole following tamoxifen as extended adjuvant therapy in receptor-positive breast cancer: updated findings from NCIC CTG MA.17. J Natl Cancer Inst. Sep. 7. 2005;97(17):1262-71. Not eligible target population. [pmid: 16145047].
971 Goss PE, Ingle JN, Martino S, et al. Efficacy of letrozole extended adjuvant therapy according to estrogen receptor and progesterone receptor status of the primary tumor: National Cancer Institute of Canada Clinical Trials Group MA.17. J Clin Oncol. May. 20. 2007;25(15):2006-11. Not eligible target population. [pmid: 17452676].
972 Goss PE, Ingle JN, Martino S, et al. A randomized trial of letrozole in postmenopausal women after five years of tamoxifen therapy for early-stage breast cancer. N Engl J Med. Nov. 6. 2003;349(19):1793-802. Not eligible target population. [pmid: 14551341].
973 Goss PE, Ingle JN, Pater JL, et al. Late extended adjuvant treatment with letrozole improves outcome in women with early-stage breast cancer who complete 5 years of tamoxifen. J Clin Oncol. Apr. 20. 2008;26(12):1948-55. Not eligible target population. [pmid: 18332475].
974 Goss PE, Richardson H, Chlebowski R, et al. National Cancer Institute of Canada Clinical Trials Group MAP.3 Trial: evaluation of exemestane to prevent breast cancer in postmenopausal women. Clin Breast Cancer. Dec. 2007;7(11):895-900. Not eligible target population. [pmid: 18269782].
975 Goss PE, Winer EP, Tannock IF, et al. Randomized phase III trial comparing the new potent and selective third-generation aromatase inhibitor vorozole with megestrol acetate in postmenopausal advanced breast cancer patients. North American Vorozole Study Group. J Clin Oncol. Jan. 1999;17(1):52-63. Not eligible target population. [pmid: 10458218].
976 Gotte M, Kersting C, Radke I, et al. An expression signature of syndecan-1 (CD138), E-cadherin and c-met is associated with factors of angiogenesis and lymphangiogenesis in ductal breast carcinoma in situ. Breast Cancer Res. 2007;9(1):R8. Not eligible outcomes. [pmid: 17244359].
977 Gottlieb JR, McKinney P, Walkinshaw MD, et al. Occult breast carcinoma in patients undergoing reduction mammaplasty. Aesthetic Plast Surg. Fall. 1989;13(4):279-83. Case Reports. [pmid: 2556896].
978 Gottlieb V, Muench AG, Rich JD, et al. Carcinoma in augmented breasts. Ann Plast Surg. Jan. 1984;12(1):67-9. Case Reports. [pmid: 6322665].
979 Gottwald L, Gora E, Korczynski J, et al. Primary uterine rhabdomyosarcoma in a patient with a history of breast cancer and gastrointestinal stromal tumor. J Obstet Gynaecol Res. Aug. 2008;34(4 Pt 2):721-5. Case Reports. [pmid: 18840190].
980 Gould VE, Wolff M, Mottet NK. Morphologic features of mammary carcinomas in women taking hormonal contraceptives. Am J Clin Pathol. Feb. 1972;57(2):139-43. Not eligible outcomes. [pmid: 4333281].
981 Goyal A, Douglas-Jones A, Monypenny I, et al. Is there a role of sentinel lymph node biopsy in ductal carcinoma in situ?: analysis of 587 cases. Breast Cancer Res Treat. Aug. 2006;98(3):311-4. Not eligible outcomes. [pmid: 16552627].
982 Goyal S, Puri T, Gupta R, et al. Accessory breast tissue in axilla masquerading as breast cancer recurrence. J Cancer Res Ther. Apr–Jun. 2008;4(2):95-6. Case Reports. [pmid: 18688128].
983 Gradishar WJ, Bellon JR, Gadd MA, et al. Case records of the Massachusetts General Hospital. Case 30-2008. A 47-year-old woman with a mass in the breast and a solitary lesion in the spine. N Engl J Med. Sep. 25. 2008;359(13):1382-91. Case Reports. [pmid: 18815400].
984 Graham MD, Lakhani S, Gazet JC. Breast conserving surgery in the management of in situ breast carcinoma. Eur J Surg Oncol. Jun. 1991;17(3):258-64. Not eligible level of evidence. [pmid: 1646128].
985 Graversen HP, Blichert-Toft M, Dyreborg U, et al. Strategy in the management of in situ carcinomas of the breast: clinical, diagnostic, and surgical aspects. Recent Results Cancer Res. 1990;119:165-74. Review. [pmid: 2173082].
986 Gray LA, Barnes ML. Effects of estrogenic therapy on the breast. South Med J. Jul. 1971;64(7):835-8. Not eligible outcomes. [pmid: 4326230].
987 Gray RJ, Pockaj BA, Karstaedt PJ. Navigating murky waters: a modern treatment algorithm for nipple discharge. Am J Surg. Dec. 2007;194(6):850-4. discussion 4-5. Not eligible target population. [pmid: 18005783].
988 Green AR, Green VL, White MC, et al. Expression of cytokine messenger RNA in normal and neoplastic human breast tissue: identification of interleukin-8 as a potential regulatory factor in breast tumours. Int J Cancer. Sep. 17. 1997;72(6):937-41. Not eligible outcomes. [pmid: 9378554].
989 Greenberg D, McIntyre H, Gregory M, et al. Ductography: a pictorial essay of common pathologies. Breast J. Sep–Oct. 2004;10(5):454-7. Case Reports. [pmid: 15327504].
990 Greene T, Tartter PI, Smith SR, et al. The significance of surgical margins for patients with atypical ductal hyperplasia. Am J Surg. Oct. 2006;192(4):499-501. Not eligible target population. [pmid: 16978959].
991 Gribbestad IS, Nilsen G, Fjosne H, et al. Contrast-enhanced magnetic resonance imaging of the breast. Acta Oncol. 1992;31(8):833-42. Not eligible outcomes. [pmid: 1337832].
992 Griffen MM, Welling RE. Needle-localized biopsy of the breast. Surg Gynecol Obstet. Feb. 1990;170(2):145-8. Not eligible outcomes. [pmid: 2154039].
993 Griffin A, Frazee RC. Treatment of intraductal breast cancer--noncomedo type. Am Surg. Feb. 1993;59(2):106-9. Not eligible level of evidence. [pmid: 8386487].
994 Grin A, Horne G, Ennis M, et al. Measuring extent of ductal carcinoma in situ in breast excision specimens: a comparison of 4 methods. Arch Pathol Lab Med. Jan. 2009;133(1):31-7. Not eligible outcomes. [pmid: 19123733].
995 Grondahl-Hansen J, Christensen IJ, Rosenquist C, et al. High levels of urokinase-type plasminogen activator and its inhibitor PAI-1 in cytosolic extracts of breast carcinomas are associated with poor prognosis. Cancer Res. Jun. 1. 1993;53(11):2513-21. Not eligible target population. [pmid: 8388317].
996 Grotting JC. The free abdominoplasty flap for immediate breast reconstruction. Ann Plast Surg. Oct. 1991;27(4):351-4. Case Reports. [pmid: 1663325].
997 Grove A, Deibjerg Kristensen L. Intraductal carcinoma within a phyllodes tumor of the breast: a case report. Tumori. Apr. 30. 1986;72(2):187-90. Case Reports. [pmid: 3010519].
998 Groves AM, Warren RM, Godward S, et al. Characterization of pure high-grade DCIS on magnetic resonance imaging using the evolving breast MR lexicon terminology: can it be differentiated from pure invasive disease. Magn Reson Imaging. Jul. 2005;23(6):733-8. Not eligible level of evidence. [pmid: 16198828].
999 Grunewald K, Haun M, Urbanek M, et al. Mammaglobin gene expression: a superior marker of breast cancer cells in peripheral blood in comparison to epidermal-growth-factor receptor and cytokeratin-19. Lab Invest. Jul. 2000;80(7):1071-7. Not eligible outcomes. [pmid: 10908152].
1000 Grunwald S, Bojahr B, Schwesinger G, et al. Mammary ductoscopy for the evaluation of nipple discharge and comparison with standard diagnostic techniques. J Minim Invasive Gynecol. Sep–Oct. 2006;13(5):418-23. Not eligible outcomes. [pmid: 16962525].
1001 Grunwald S, Heyer H, Paepke S, et al. Diagnostic value of ductoscopy in the diagnosis of nipple discharge and intraductal proliferations in comparison to standard methods. Onkologie. May. 2007;30(5):243-8. Not eligible outcomes. [pmid: 17460418].
1002 Guerrieri-Gonzaga A, Robertson C, Bonanni B, et al. Preliminary results on safety and activity of a randomized, double-blind, 2 x 2 trial of low-dose tamoxifen and fenretinide for breast cancer prevention in premenopausal women. J Clin Oncol. Jan. 1. 2006;24(1):129-35. Not eligible outcomes. [pmid: 16382122].
1003 Gufler H, Buitrago-Tellez CH, Madjar H, et al. Ultrasound demonstration of mammographically detected microcalcifications. Acta Radiol. May. 2000;41(3):217-21. Not eligible outcomes. [pmid: 10866074].
1004 Gugle A, Malpathak V, Zawar V, et al. Carcinoma erysipeloides: an unusual presentation mimicking radiation dermatitis. Dermatol Online J. 2008;14(2):26. Case Reports. [pmid: 18700129].
1005 Gui GP, Kadayaprath G, Darhouse N, et al. Clinical outcome and service implications of screening women at increased breast cancer risk from a family history. Eur J Surg Oncol. Sep. 2006;32(7):719-24. Not eligible outcomes. [pmid: 16784834].
1006 Guidozzi F, Daponte A. Estrogen replacement therapy for ovarian carcinoma survivors: A randomized controlled trial. Cancer. Sep. 15. 1999;86(6):1013-8. Not eligible target population. [pmid: 10491528].
1007 Guler G, Uner A, Guler N, et al. Concordant loss of fragile gene expression early in breast cancer development. Pathol Int. Aug. 2005;55(8):471-8. Not eligible outcomes. [pmid: 15998374].
1008 Gump FE. The management of in situ breast cancer. Compr Ther. Jun. 1992;18(6):1-4. Secondary data analysis. [pmid: 1324823].
1009 Gump FE, Jicha DL, Ozello L. Ductal carcinoma in situ (DCIS): a revised concept. Surgery. Nov. 1987;102(5):790-5. Not eligible level of evidence. [pmid: 2823405].
1010 Gunasegaram R, Peh KL, Loganath A, et al. Inappropriate luteinizing hormone concentration in human breast cancer. Aust N Z J Surg. Apr. 1985;55(2):127-31. Not eligible outcomes. [pmid: 2994618].
1011 Gunhan-Bilgen I, Oktay A. Paget’s disease of the breast: clinical, mammographic, sonographic and pathologic findings in 52 cases. Eur J Radiol. Nov. 2006;60(2):256-63. Not eligible target population. [pmid: 16887314].
1012 Guo HQ, Gao M, Ma J, et al. Analysis of the cellular centrosome in fine-needle aspirations of the breast. Breast Cancer Res. 2007;9(4):R48. Not eligible target population. [pmid: 17662154].
1013 Guo LL, Gao P, Wu YG, et al. Alteration of cyclin D1 in Chinese patients with breast carcinoma and its correlation with Ki-67, pRb, and p53. Arch Med Res. Nov. 2007;38(8):846-52. Not eligible outcomes. [pmid: 17923265].
1014 Gupta A, Deshpande CG, Badve S. Role of E-cadherins in development of lymphatic tumor emboli. Cancer. May. 1. 2003;97(9):2341-7. Not eligible outcomes. [pmid: 12712492].
1015 Gupta D, Nath M, Layfield LJ. Utility of four-quadrant random sections in mastectomy specimens. Breast J. Jul–Aug. 2003;9(4):307-11. Not eligible target population. [pmid: 12846866].
1016 Gupta S, Joshi K, Wig JD, et al. Intratumoral FOXP3 expression in infiltrating breast carcinoma: Its association with clinicopathologic parameters and angiogenesis. Acta Oncol. 2007;46(6):792-7. Not eligible outcomes. [pmid: 17653902].
1017 Guth AA, Mercado C, Roses DF, et al. Intramammary lymph nodes and breast cancer: a marker for disease severity, or just another lymph node. Am J Surg. Oct. 2006;192(4):502-5. Not eligible outcomes. [pmid: 16978960].
1018 Guzman J, Ruckmann A, Glaser A, et al. DNA cytophotometric analysis of breast cancer. Follow-up for 10 years. Anal Quant Cytol Histol. Dec. 1992;14(6):427-32. Not eligible outcomes. [pmid: 1337966].
1019 Haffty BG, Peschel RE, Papadopoulos D, et al. Radiation therapy for ductal carcinoma in situ of the breast. Conn Med. Sep. 1990;54(9):482-4. Not eligible level of evidence. [pmid: 2171869].
1020 Haga S, Watanabe O, Shimizu T, et al. The clinical value of tissue carcinoembryonic antigen in breast cancer. Jpn J Surg. May. 1991;21(3):278-83. Not eligible outcomes. [pmid: 1649933].
1021 Hahn M, Kuner RP, Scheler P, et al. Sonographic criteria for the confirmation of implant rotation and the development of an implant-capsule-interaction (“interface”) in anatomically formed textured breast implants with texturised Biocell-surface. Ultraschall in der Medizin. Aug. 2008;29(4):399-404. Not eligible exposure. [pmid: 17610178].
1022 Haid A, Knauer M, Dunzinger S, et al. Intra-operative sonography: a valuable aid during breast-conserving surgery for occult breast cancer. Ann Surg Oncol. Nov. 2007;14(11):3090-101. Not eligible outcomes. [pmid: 17593330].
1023 Haier J, Haensch W, Schon M. Leiomyoma as a rare differential diagnosis of Paget’s disease of the nipple. Acta Obstet Gynecol Scand. May. 1997;76(5):490-1. Not eligible target population. [pmid: 9197458].
1024 Haile RW, Thomas DC, McGuire V, et al. BRCA1 and BRCA2 mutation carriers, oral contraceptive use, and breast cancer before age 50. Cancer Epidemiol Biomarkers Prev. Oct. 2006;15(10):1863-70. Not eligible outcomes. [pmid: 17021353].
1025 Hainsworth PJ, Raphael KL, Stillwell RG, et al. Cytogenetic features of twenty-six primary breast cancers. Cancer Genet Cytogenet. Jun. 1991;53(2):205-18. Not eligible outcomes. [pmid: 1648438].
1026 Hainsworth PJ, Tjandra JJ, Stillwell RG, et al. Detection and significance of occult metastases in node-negative breast cancer. Br J Surg. Apr. 1993;80(4):459-63. Not eligible outcomes. [pmid: 8388305].
1027 Half E, Tang XM, Gwyn K, et al. Cyclooxygenase-2 expression in human breast cancers and adjacent ductal carcinoma in situ. Cancer Res. Mar. 15. 2002;62(6):1676-81. Not eligible outcomes. [pmid: 11912139].
1028 Hall JC, Hall JL. The measurement of wound infection after breast surgery. Breast J. Sep–Oct. 2004;10(5):412-5. Not eligible target population. [pmid: 15327494].
1029 Hall L, Craig RK, Campbell PN. mRNA species directing synthesis of milk proteins in normal and tumour tissue from human mammary gland. Nature. Jan. 4. 1979;277(5691):54-6. Not eligible outcomes. [pmid: 233259].
1030 Hamada N, Ogawa Y, Nishioka A, et al. An elderly patient with DCIS of the breast effectively treated with toremifene alone. Oncol Rep. May–Jun. 2002;9(3):475-8. Case Reports. [pmid: 11956612].
1031 Hamamoto R, Silva FP, Tsuge M, et al. Enhanced SMYD3 expression is essential for the growth of breast cancer cells. Cancer Sci. Feb. 2006;97(2):113-8. Not eligible outcomes. [pmid: 16441421].
1032 Hamby LS, McGrath PC, Stelling CB, et al. Management of mammographic indeterminate lesions. First place winner of the Conrad Jobst Award in the Gold Medal paper competition. Am Surg. Jan. 1993;59(1):4-8. Not eligible outcomes. [pmid: 8386912].
1033 Hameed O, Ghali VS, Tartter PI, et al. Immunohistochemical staining for cyclin D1 and Ki-67 aids in the stratification of atypical ductal hyperplasia diagnosed on breast core biopsy. Am J Clin Pathol. Dec. 2005;124(6):862-72. Not eligible outcomes. [pmid: 16416735].
1034 Hamilton CR, Buchanan RB. Radiotherapy for ductal carcinoma in situ detected by screening. BMJ. Jul. 28. 1990;301(6745):224-5. Comment. [pmid: 2168228].
1035 Hamilton CS, Nield JM, Adler GF, et al. Results of breast conserving treatment of breast cancer. Acta Oncol. 1990;29(2):137-42. Not eligible target population. [pmid: 2159312].
1036 Hamilton LJ, Evans AJ, Wilson AR, et al. Breast imaging findings in women with BRCA1- and BRCA2-associated breast carcinoma. Clin Radiol. Oct. 2004;59(10):895-902. Not eligible level of evidence. [pmid: 15451348].
1037 Hamm JT, Allegra JC. New hormonal approaches to the treatment of breast cancer. Crit Rev Oncol Hematol. 1991;11(1):29-41. Not eligible target population. [pmid: 1652976].
1038 Hammam T, McFadzean RM, Ironside JW. Anti-hu paraneoplastic syndrome presenting as bilateral sixth cranial nerve palsies. J Neuroophthalmol. Jun. 2005;25(2):101-4. Case Reports. [pmid: 15937431].
1039 Han BK, Choe YH, Ko YH, et al. Stereotactic core-needle biopsy of non-mass calcifications: outcome and accuracy at long-term follow-up. Korean J Radiol. Oct–Dec. 2003;4(4):217-23. Not eligible outcomes. [pmid: 14726638].
1040 Han S, Ahn SH, Park K, et al. P16INK4a protein expression is associated with poor survival of the breast cancer patients after CMF chemotherapy. Breast Cancer Res Treat. Dec. 2001;70(3):205-12. Not eligible target population. [pmid: 11804184].
1041 Han S, Kim JS, Kim BS, et al. 99mTc-MIBI scan in mammary Pagets disease: a case report. J Korean Med Sci. Dec. 1999;14(6):675-8. Not eligible target population. [pmid: 10642948].
1042 Hann L, Ducatman BS, Wang HH, et al. Nonpalpable breast lesions: evaluation by means of fine-needle aspiration cytology. Radiology. May. 1989;171(2):373-6. Not eligible outcomes. [pmid: 2539608].
1043 Hann SK, Rhoe BS, Kang WH, et al. Self limited dermal invasion of keratinocytes in maculopapular eruptions after systemic chemotherapy. J Dermatol. Feb. 1993;20(2):94-101. Case Reports. [pmid: 7683027].
1044 Hanna W, Alowami S, Malik A. The role of HER-2/neu oncogene and vimentin filaments in the production of the Paget’s phenotype. Breast J. Nov–Dec. 2003;9(6):485-90. Not eligible target population. [pmid: 14616943].
1045 Hanna W, AL-M J, Malik A. Aggressive giant fibroepithelial lesion with unusual vascular stroma--a case report. Mod Pathol. Aug. 2003;16(8):823-7. Case Reports. [pmid: 12920228].
1046 Hanna WC, Demyttenaere SV, Ferri LE, et al. The use of stereotactic excisional biopsy in the management of invasive breast cancer. World J Surg. Nov. 2005;29(11):1490-4. discussion 5-6. Not eligible target population. [pmid: 16240063].
1047 Hannemann J, Velds A, Halfwerk JB, et al. Classification of ductal carcinoma in situ by gene expression profiling. Breast Cancer Res. 2006;8(5):R61. Not eligible outcomes. [pmid: 17069663].
1048 Hansen NM, Grube BJ, Giuliano AE. The time has come to change the algorithm for the surgical management of early breast cancer. Arch Surg. Oct. 2002;137(10):1131-5. Not eligible target population. [pmid: 12361418].
1049 Hara T, Yamaguchi T, Ishihara T, et al. Diagnosis and patient management of intraductal papillary-mucinous tumor of the pancreas by using peroral pancreatoscopy and intraductal ultrasonography. Gastroenterology. Jan. 2002;122(1):34-43. Not eligible target population. [pmid: 11781278].
1050 Hareyama M, Saito A, Ookubo T, et al. A case report of Paget’s disease of the breast treated with radiotherapy alone. Radiat Med. Jul–Aug. 1990;8(4):152-4. Case Reports. [pmid: 2177903].
1051 Haroske G, Kunze KD, Theissig F. Prognostic significance of image cytometry DNA parameters in tissue sections from breast and gastric cancers. Anal Cell Pathol. Jan. 1991;3(1):11-24. Not eligible target population. [pmid: 1848088].
1052 Harper JL, Jenrette JM, Vanek KN, et al. Acute complications of MammoSite brachytherapy: a single institution’s initial clinical experience. Int J Radiat Oncol Biol Phys. Jan. 1. 2005;61(1):169-74. Not eligible target population. [pmid: 15629608].
1053 Harper-Wynne CL, Sacks NP, Shenton K, et al. Comparison of the systemic and intratumoral effects of tamoxifen and the aromatase inhibitor vorozole in postmenopausal patients with primary breast cancer. J Clin Oncol. Feb. 15. 2002;20(4):1026-35. Not eligible target population. [pmid: 11844826].
1054 Harris AL, Dowsett M, Smith IE, et al. Hydrocortisone alone vs hydrocortisone plus aminoglutethimide: a comparison of the endocrine effects in postmenopausal breast cancer. Eur J Cancer Clin Oncol. Apr. 1984;20(4):463-9. Not eligible target population. [pmid: 6233150].
1055 Harris AT. Case 41: Ductal carcinoma in situ. Radiology. Dec. 2001;221(3):770-3. Case Reports. [pmid: 11719676].
1056 Harris BE, Carpenter JT, Diasio RB. Severe 5-fluorouracil toxicity secondary to dihydropyrimidine dehydrogenase deficiency. A potentially more common pharmacogenetic syndrome. Cancer. Aug. 1. 1991;68(3):499-501. Case Reports. [pmid: 1648430].
1057 Harris EE, Schultz DJ, Jones HA, et al. Factors associated with residual disease on re-excision in patients with ductal carcinoma in situ of the breast. Cancer J. Jan–Feb. 2003;9(1):42-8. Not eligible outcomes. [pmid: 12602767].
1058 Harris M. Pseudoadenoid cystic carcinoma of the breast. Arch Pathol Lab Med. Jun. 1977;101(6):307-9. Case Reports. [pmid: 193457].
1059 Harrison M, Coyne JD, Gorey T, et al. Comparison of cytomorphological and architectural heterogeneity in mammographically-detected ductal carcinoma in situ. Histopathology. May. 1996;28(5):445-50. Not eligible outcomes. [pmid: 8735720].
1060 Harrison M, Magee HM, O’Loughlin J, et al. Chromosome 1 aneusomy, identified by interphase cytogenetics, in mammographically detected ductal carcinoma in situ of the breast. J Pathol. Mar. 1995;175(3):303-9. Not eligible outcomes. [pmid: 7745499].
1061 Harrison RI, Glenn DC, Niesche FW, et al. Surgical management of breast cancer. Experience of the Central Sydney Area Health Service Breast X-ray Programme, 1988-1991. Med J Aust. May. 16. 1994;160(10):617-20. Not eligible outcomes. [pmid: 8177106].
1062 Harshfield DL, Nokes SR. Radiological case of the month. Comedocarcinoma. J Ark Med Soc. Jul. 1991;88(2):105-6. Case Reports. [pmid: 1655694].
1063 Hartrampf CR Jr, Noel RT, Drazan L, et al. Ruben’s fat pad for breast reconstruction: a peri-iliac soft-tissue free flap. Plast Reconstr Surg. Feb. 1994;93(2):402-7. Case Reports. [pmid: 8310036].
1064 Harvey DG, Fechner RE. Atypical lobular and papillary lesions of the breast: a follow-up study of 30 cases. South Med J. Apr. 1978;71(4):361-4. Not eligible outcomes. [pmid: 205000].
1065 Harvey JM, Sterrett GF, Frost FA. Atypical ductal hyperplasia and atypia of uncertain significance in core biopsies from mammographically detected lesions: correlation with excision diagnosis. Pathology. Oct. 2002;34(5):410-6. Not eligible outcomes. [pmid: 12408338].
1066 Harvey JM, Sterrett GF, McEvoy S, et al. Pathology reporting of breast cancer: trends in 1989-1999 following the introduction of mammographic screening in Western Australia. Pathology. Oct. 2005;37(5):341-6. Not eligible outcomes. [pmid: 16194843].
1067 Hashimoto K, Koga T, Shintomi Y, et al. The anticancer effect of antineoplaston A-10 on human breast cancer serially transplanted to athymic mice. Nippon Gan Chiryo Gakkai Shi. Jan. 20. 1990;25(1):1-5. Not eligible target population. [pmid: 2157780].
1068 Hassell P, Klein-Parker H, Worth A, et al. Radial sclerosing lesions of the breast: mammographic and pathologic correlation. Can Assoc Radiol J. Dec. 1999;50(6):370-5. Not eligible outcomes. [pmid: 10659059].
1069 Hassell PR, Olivotto IA, Mueller HA, et al. Early breast cancer: detection of recurrence after conservative surgery and radiation therapy. Radiology. Sep. 1990;176(3):731-5. Not eligible outcomes. [pmid: 2167500].
1070 Hassett MJ, Hughes ME, Niland JC, et al. Selecting high priority quality measures for breast cancer quality improvement. Med Care. Aug. 2008;46(8):762-70. Guideline. [pmid: 18665055].
1071 Hasson A, Requena L, Arias D, et al. Linear pemphigus vulgaris along a surgical scar. Dermatologica. 1991;182(3):191-2. Case Reports. [pmid: 1652525].
1072 Hastrich DJ, Dunn JM, Armstrong JS, et al. Diagnostic and therapeutic aspects of fine-wire localization biopsy for impalpable breast cancer. Br J Surg. Oct. 1992;79(10):1038-41. Not eligible outcomes. [pmid: 1330196].
1073 Hata T, Takahashi H, Watanabe K, et al. Magnetic resonance imaging for preoperative evaluation of breast cancer: a comparative study with mammography and ultrasonography. J Am Coll Surg. Feb. 2004;198(2):190-7. Not eligible outcomes. [pmid: 14759774].
1074 Hausner RJ, Schoen FJ, Pierson KK. Foreign-body reaction to silicone gel in axillary lymph nodes after an augmentation mammaplasty. Plast Reconstr Surg. Sep. 1978;62(3):381-4. Case Reports. [pmid: 211534].
1075 Hauth EA, Jaeger HJ, Lubnau J, et al. MR-guided vacuum-assisted breast biopsy with a handheld biopsy system: clinical experience and results in postinterventional MR mammography after 24 h. European radiology. Jan. 2008;18(1):168-76. Not eligible exposure. [pmid: 17609959].
1076 Hayashi AH, Silver SF, van der Westhuizen NG, et al. Treatment of invasive breast carcinoma with ultrasound-guided radiofrequency ablation. Am J Surg. May. 2003;185(5):429-35. Not eligible target population. [pmid: 12727562].
1077 Hayes AG, Chesney TM. Metastatic adenocarcinoma of the breast located within a benign intradermal nevus. Am J Dermatopathol. Jun. 1993;15(3):280-2. Case Reports. [pmid: 8390797].
1078 Hayes MM, Peterse JL, Yavuz E, et al. Squamous cell carcinoma in situ of the breast: a light microscopic and immunohistochemical study of a previously undescribed lesion. Am J Surg Pathol. Sep. 2007;31(9):1414-9. Not eligible outcomes. [pmid: 17721198].
1079 Hayman JA, Kabeto MU, Schipper MJ, et al. Assessing the benefit of radiation therapy after breast-conserving surgery for ductal carcinoma-in-situ. J Clin Oncol. Aug. 1. 2005;23(22):5171-7. Not eligible outcomes. [pmid: 16051959].
1080 Healy CE, Dijkstra B, Walsh M, et al. Nipple adenoma: a differential diagnosis for Paget’s disease. Breast J. Jul–Aug. 2003;9(4):325-6. Not eligible target population. [pmid: 12846871].
1081 Heaphy CM, Bisoffi M, Joste NE, et al. Genomic instability demonstrates similarity between DCIS and invasive carcinomas. Breast Cancer Res Treat. 2008. Sep. 11. Not eligible outcomes.
1082 Hegg R, De Souza AZ, Pestana CB, et al. Tissue carcinoembryonic antigen in the prognosis of early invasive breast cancer. Breast Cancer Res Treat. May. 1990;15(3):213-6. Not eligible outcomes. [pmid: 2164851].
1083 Heintz NH, Leslie KO, Rogers LA, et al. Amplification of the c-erb B-2 oncogene and prognosis of breast adenocarcinoma. Arch Pathol Lab Med. Feb. 1990;114(2):160-3. Not eligible outcomes. [pmid: 1967929].
1084 Helbich TH, Mayr W, Schick S, et al. Coaxial technique: approach to breast core biopsies. Radiology. Jun. 1997;203(3):684-90. Not eligible outcomes. [pmid: 9169689].
1085 Helle SI, Geisler S, Aas T, et al. Plasma insulin-like growth factor binding protein-3 proteolysis is increased in primary breast cancer. Br J Cancer. Jul. 6. 2001;85(1):74-7. Not eligible exposure. [pmid: 11437405].
1086 Heller KS, Rosen PP, Schottenfeld D, et al. Male breast cancer: a clinicopathologic study of 97 cases. Ann Surg. Jul. 1978;188(1):60-5. Not eligible target population. [pmid: 208472].
1087 Helvie MA, Wilson TE, Roubidoux MA, et al. Mammographic appearance of recurrent breast carcinoma in six patients with TRAM flap breast reconstructions. Radiology. Dec. 1998;209(3):711-5. Case Reports. [pmid: 9844663].
1088 Hemminki K, Granstrom C. Morphological types of breast cancer in family members and multiple primary tumours: is morphology genetically determined?. Breast Cancer Res. 2002;4(4):R7. Not eligible target population. [pmid: 12100745].
1089 Hendry P, Whitford P. Li-Fraumeni syndrome: a case report and discussion. Scott Med J. Aug. 2005;50(3):130-1. Case Reports. [pmid: 16164004].
1090 Henne-Bruns D, Kremer B, Meyer-Pannwitt U, et al. Partial duodenopancreatectomy with radical lymphadenectomy in patients with pancreatic and periampullary carcinomas: initial results. Hepatogastroenterology. Apr. 1993;40(2):145-9. Not eligible target population. [pmid: 8099561].
1091 Hennessy BT, Gilcrease MZ, Kim E, et al. Breast carcinoma with neuroendocrine differentiation and myocardial metastases. Clin Breast Cancer. Dec. 2007;7(11):892-4. Not eligible outcomes. [pmid: 18269781].
1092 Hennig EM, Suo Z, Thoresen S, et al. Human papillomavirus 16 in breast cancer of women treated for high grade cervical intraepithelial neoplasia (CIN III). Breast Cancer Res Treat. Jan. 1999;53(2):121-35. Not eligible outcomes. [pmid: 10326789].
1093 Henry JA, Nicholson S, Hennessy C, et al. Expression of the oestrogen regulated pNR-2 mRNA in human breast cancer: relation to oestrogen receptor mRNA levels and response to tamoxifen therapy. Br J Cancer. Jan. 1990;61(1):32-8. Not eligible outcomes. [pmid: 2153395].
1094 Henry JA, Piggott NH, Mallick UK, et al. pNR-2/pS2 immunohistochemical staining in breast cancer: correlation with prognostic factors and endocrine response. Br J Cancer. Apr. 1991;63(4):615-22. Not eligible exposure. [pmid: 1850611].
1095 Henry NL, Stearns V, Flockhart DA, et al. Drug interactions and pharmacogenomics in the treatment of breast cancer and depression. Am J Psychiatry. Oct. 2008;165(10):1251-5. Case Reports. [pmid: 18829880].
1096 Hermann G, Janus C, Schwartz IS, et al. Occult malignant breast lesions in 114 patients: relationship to age and the presence of microcalcifications. Radiology. Nov. 1988;169(2):321-4. Not eligible outcomes. [pmid: 2845470].
1097 Hermann G, Keller RJ, Halton K, et al. Nonpalpable ductal carcinoma in situ versus infiltrating carcinoma of the breast--can they be differentiated by mammography. Can Assoc Radiol J. Jun. 1991;42(3):219-22. Not eligible outcomes. [pmid: 1647259].
1098 Hermann G, Keller RJ, Schwartz IS, et al. Nonpalpable breast masses: radiologic predictability of malignancy. Can Assoc Radiol J. Jun. 1990;41(3):130-2. Not eligible outcomes. [pmid: 2162236].
1099 Hermann RE, Esselstyn CB Jr, Crile G Jr, et al. Results of conservative operations for breast cancer. Arch Surg. Jun. 1985;120(6):746-51. Not eligible level of evidence. [pmid: 2988482].
1100 Hermann RE, Esselstyn CB Jr, Grundfest-Broniatowski S, et al. Partial mastectomy without radiation is adequate treatment for patients with stages 0 and I carcinoma of the breast. Surg Gynecol Obstet. Sep. 1993;177(3):247-53. Not eligible outcomes. [pmid: 8395083].
1101 Hershman D, Sundararajan V, Jacobson JS, et al. Outcomes of tamoxifen chemoprevention for breast cancer in very high-risk women: a cost-effectiveness analysis. J Clin Oncol. Jan. 1. 2002;20(1):9-16. Not eligible outcomes. [pmid: 11773148].
1102 Hetelekidis S, Collins L, Silver B, et al. Predictors of local recurrence following excision alone for ductal carcinoma in situ. Cancer. Jan. 15. 1999;85(2):427-31. Not eligible level of evidence. [pmid: 10023711].
1103 Hieken TJ, Farolan M, D’Alessandro S, et al. Predicting the biologic behavior of ductal carcinoma in situ: an analysis of molecular markers. Surgery. Oct. 2001;130(4):593-600. discussion −1. Not eligible level of evidence. [pmid: 11602889].
1104 Hildenbrand R, Arens N. Protein and mRNA expression of uPAR and PAI-1 in myoepithelial cells of early breast cancer lesions and normal breast tissue. Br J Cancer. Aug. 2. 2004;91(3):564-71. Not eligible outcomes. [pmid: 15226768].
1105 Hildenbrand R, Leitz M, Magdolen V, et al. Validation of immunolocalization of the urokinase receptor expression in ductal carcinoma in situ of the breast: comparison with detection by non-isotopic in-situ hybridization. Histopathology. Jun. 2000;36(6):499-504. Not eligible outcomes. [pmid: 10849091].
1106 Hildenbrand R, Schaaf A. The urokinase-system in tumor tissue stroma of the breast and breast cancer cell invasion. Int J Oncol. Jan. 2009;34(1):15-23. Not eligible outcomes. [pmid: 19082473].
1107 Hilderly LJ, Wilcox PM, Pollock RE, et al. Options for breast cancer treatment. Cancer Pract. May–Jun. 1996;4(3):121-4. Case Reports. [pmid: 8826139].
1108 Hilf R, Wittliff JL, Rector WD, et al. Studies on certain cytoplasmic enzymes and specific estrogen receptors in human breast cancer and in nonmalignant diseases of the breast. Cancer Res. Sep. 1973;33(9):2054-62. Not eligible target population. [pmid: 4353478].
1109 Hill-Kayser CE, Harris EE, Hwang WT, et al. Twenty-year incidence and patterns of contralateral breast cancer after breast conservation treatment with radiation. Int J Radiat Oncol Biol Phys. Dec. 1. 2006;66(5):1313-9. Not eligible target population. [pmid: 16997501].
1110 Hillner BE, Desch CE, Carlson RW, et al. Trade-offs between survival and breast preservation for three initial treatments of ductal carcinoma-in-situ of the breast. J Clin Oncol. Jan. 1996;14(1):70-7. Not eligible target population. [pmid: 8558224].
1111 Hilson JB, Schnitt SJ, Collins LC. Phenotypic alterations in ductal carcinoma in situ-associated myoepithelial cells: biologic and diagnostic implications. Am J Surg Pathol. Feb. 2009;33(2):227-32. Not eligible outcomes. [pmid: 18936688].
1112 Hiramatsu H, Bornstein BA, Recht A, et al. Local recurrence after conservative surgery and radiation therapy for ductal carcinoma in situ: Possible importance of family history. Cancer J Sci Am. May–Jun. 1995;1(1):55-61. Not eligible level of evidence. [pmid: 9166455].
1113 Hiraoka T, Uchino R, Kanemitsu K, et al. Combination of intraoperative radiation with resection of cancer of the pancreas. Int J Pancreatol. Aug–Nov. 1990;7(1-3):201-7. Not eligible target population. [pmid: 1964472].
1114 Hird RB, Chang A, Cimmino V, et al. Impact of estrogen receptor expression and other clinicopathologic features on tamoxifen use in ductal carcinoma in situ. Cancer. May. 15. 2006;106(10):2113-8. Not eligible outcomes. [pmid: 16596655].
1115 Hirsch A. Integrative tumor board: recurrent breast cancer or new primary? Radiation oncology. Integr Cancer Ther. Sep. 2003;2(3):272-6. Case Reports. [pmid: 15035891].
1116 Hislop TG, Coldman AJ, Olivotto IA, et al. Local and regional therapy for women with breast cancer in British Columbia. Breast J. May–Jun. 2003;9(3):192-9. Not eligible target population. [pmid: 12752627].
1117 Hislop TG, Olivotto IA, Coldman AJ, et al. Variations in breast conservation surgery for women with axillary lymph node negative breast cancer in British Columbia. Can J Public Health. Nov–Dec. 1996;87(6):390-4. Not eligible target population. [pmid: 9009395].
1118 Hoang MP, Maitra A, Gazdar AF, et al. Primary mammary small-cell carcinoma: a molecular analysis of 2 cases. Hum Pathol. Jul. 2001;32(7):753-7. Case Reports. [pmid: 11486176].
1119 Hoehne FM, Taylor E. Trends in breast cancer at a county hospital. Am Surg. Feb. 2005;71(2):159-63. Not eligible target population. [pmid: 16022017].
1120 Hofman P, Hsi BL, Manie S, et al. High expression of the antigen recognized by the monoclonal antibody GB24 on human breast carcinomas: a preventive mechanism of malignant tumor cells against complement attack. Breast Cancer Res Treat. 1994;32(2):213-9. Not eligible outcomes. [pmid: 7532466].
1121 Holboke MJ, Tromberg BJ, Li X, et al. Three-dimensional diffuse optical mammography with ultrasound localization in a human subject. J Biomed Opt. Apr. 2000;5(2):237-47. Not eligible outcomes. [pmid: 10938789].
1122 Holland PA, Knox WF, Potten CS, et al. Assessment of hormone dependence of comedo ductal carcinoma in situ of the breast. J Natl Cancer Inst. Jul. 16. 1997;89(14):1059-65. Not eligible target population. [pmid: 9230888].
1123 Holland R, Connolly JL, Gelman R, et al. The presence of an extensive intraductal component following a limited excision correlates with prominent residual disease in the remainder of the breast. J Clin Oncol. Jan. 1990;8(1):113-8. Not eligible target population. [pmid: 2153190].
1124 Holland R, Hendriks JH, Vebeek AL, et al. Extent, distribution, and mammographic/histological correlations of breast ductal carcinoma in situ. Lancet. Mar. 3. 1990;335(8688):519-22. Not eligible outcomes. [pmid: 1968538].
1125 Holliday DL, Brouilette KT, Markert A, et al. Novel multicellular organotypic models of normal and malignant breast: tools for dissecting the role of the microenvironment in breast cancer progression. Breast Cancer Res. Jan. 19. 2009;11(1):R3. Not eligible target population. [pmid: 19152687].
1126 Holm N, Byrnes K, Johnson L, et al. A prospective trial on initiation factor 4E (eIF4E) overexpression and cancer recurrence in node-negative breast cancer. Ann Surg Oncol. Nov. 2008;15(11):3207-15. Not eligible target population. [pmid: 18719964].
1127 Holme TC, Reis MM, Thompson A, et al. Is mammographic microcalcification of biological significance. Eur J Surg Oncol. Jun. 1993;19(3):250-3. Not eligible outcomes. [pmid: 8390947].
1128 Honma N, Takubo K, Akiyama F, et al. Expression of GCDFP-15 and AR decreases in larger or node-positive apocrine carcinomas of the breast. Histopathology. Aug. 2005;47(2):195-201. Not eligible outcomes. [pmid: 16045781].
1129 Hoorntje LE, Peeters PH, Mali WP, et al. Is stereotactic large-core needle biopsy beneficial prior to surgical treatment in BI-RADS 5 lesions. Breast Cancer Res Treat. Jul. 2004;86(2):165-70. Not eligible outcomes. [pmid: 15319568].
1130 Hoorntje LE, Schipper ME, Peeters PH, et al. The finding of invasive cancer after a preoperative diagnosis of ductal carcinoma-in-situ: causes of ductal carcinoma-in-situ underestimates with stereotactic 14-gauge needle biopsy. Ann Surg Oncol. Aug. 2003;10(7):748-53. Not eligible outcomes. [pmid: 12900365].
1131 Hoque A, Carter J, Xia W, et al. Loss of aurora A/STK15/BTAK overexpression correlates with transition of in situ to invasive ductal carcinoma of the breast. Cancer Epidemiol Biomarkers Prev. Dec. 2003;12(12):1518-22. Not eligible outcomes. [pmid: 14693746].
1132 Hoque A, Lippman SM, Boiko IV, et al. Quantitative nuclear morphometry by image analysis for prediction of recurrence of ductal carcinoma in situ of the breast. Cancer Epidemiol Biomarkers Prev. Mar. 2001;10(3):249-59. Not eligible level of evidence. [pmid: 11303595].
1133 Hoque A, Sneige N, Sahin AA, et al. Her-2/neu gene amplification in ductal carcinoma in situ of the breast. Cancer Epidemiol Biomarkers Prev. Jun. 2002;11(6):587-90. Not eligible outcomes. [pmid: 12050101].
1134 Horie A, Nomura Y, Stemmermann GN, et al. Histopathological features and their association with steroid receptors in women with breast cancer in Fukuoka, Japan. Acta Pathol Jpn. Mar. 1984;34(2):229-39. Not eligible outcomes. [pmid: 6331061].
1135 Horiguchi J, Iino Y, Takei H, et al. Recurrence of breast cancer following local excision alone for ductal carcinoma in situ. Breast Cancer. 2001;8(1):52-7. Not eligible level of evidence. [pmid: 11180766].
1136 Horiguchi J, Iino Y, Takei H, et al. Long-term prognostic value of PCNA labeling index in primary operable breast cancer. Oncol Rep. May–Jun. 1998;5(3):641-4. Not eligible target population. [pmid: 9538167].
1137 Hornychova H, Ryska A, Betlach J, et al. Mucoepidermoid carcinoma of the breast. Neoplasma. 2007;54(2):168-72. Case Reports. [pmid: 17319792].
1138 Hoshi T, Imai M, Ogawa K. Frequent K-ras mutations and absence of p53 mutations in mucin-producing tumors of the pancreas. J Surg Oncol. Feb. 1994;55(2):84-91. Not eligible target population. [pmid: 8121190].
1139 Houssami N, Irwig L, Simpson JM, et al. Sydney Breast Imaging Accuracy Study: Comparative sensitivity and specificity of mammography and sonography in young women with symptoms. AJR Am J Roentgenol. Apr. 2003;180(4):935-40. Not eligible outcomes. [pmid: 12646432].
1140 Houvenaeghel G, Lambaudie E, Buttarelli M, et al. Margin status in invasive breast cancer. Bull Cancer. Dec. 2008;95(12):1161-70. Language. [pmid: 19091649].
1141 Howard MA, Polo K, Pusic AL, et al. Breast cancer local recurrence after mastectomy and TRAM flap reconstruction: incidence and treatment options. Plast Reconstr Surg. Apr. 15. 2006;117(5):1381-6. Not eligible outcomes. [pmid: 16641702].
1142 Howard PW, Locker AP, Dowle CS, et al. In situ carcinoma of the breast. Eur J Surg Oncol. Aug. 1989;15(4):328-32. Not eligible target population. [pmid: 2547662].
1143 Howell A, Robertson JF, Quaresma Albano J, et al. Fulvestrant, formerly ICI 182,780, is as effective as anastrozole in postmenopausal women with advanced breast cancer progressing after prior endocrine treatment. J Clin Oncol. Aug. 15. 2002;20(16):3396-403. Not eligible target population. [pmid: 12177099].
1144 Hruska CB, Boughey JC, Phillips SW, et al. Scientific Impact Recognition Award: Molecular breast imaging: a review of the Mayo Clinic experience. American Journal of Surgery. Oct. 2008;196(4):470-6. Not eligible exposure. [pmid: 18723155].
1145 Hsiung PL, Phatak DR, Chen Y, et al. Benign and malignant lesions in the human breast depicted with ultrahigh resolution and three-dimensional optical coherence tomography. Radiology. Sep. 2007;244(3):865-74. Not eligible outcomes. [pmid: 17630358].
1146 Huang CS, Wu CY, Chu JS, et al. Microcalcifications of non-palpable breast lesions detected by ultrasonography: correlation with mammography and histopathology. Ultrasound Obstet Gynecol. Jun. 1999;13(6):431-6. Not eligible outcomes. [pmid: 10423808].
1147 Huang E, Buchholz TA, Meric F, et al. Classifying local disease recurrences after breast conservation therapy based on location and histology: new primary tumors have more favorable outcomes than true local disease recurrences. Cancer. Nov. 15. 2002;95(10):2059-67. Not eligible outcomes. [pmid: 12412158].
1148 Huang J, Liang ZD, Wu TT, et al. Tumor-suppressive effect of retinoid receptor-induced gene-1 (RRIG1) in esophageal cancer. Cancer Res. Feb. 15. 2007;67(4):1589-93. Not eligible target population. [pmid: 17308098].
1149 Huemer GM, Schrenk P, Moser F, et al. Oncoplastic techniques allow breast-conserving treatment in centrally located breast cancers. Plast Reconstr Surg. Aug. 2007;120(2):390-8. Not eligible target population. [pmid: 17632339].
1150 Hundertmark S, Buhler H, Rudolf M, et al. Inhibition of 11 beta-hydroxysteroid dehydrogenase activity enhances the antiproliferative effect of glucocorticosteroids on MCF-7 and ZR-75-1 breast cancer cells. J Endocrinol. Oct. 1997;155(1):171-80. Not eligible target population. [pmid: 9390020].
1151 Hunerbein M, Raubach M, Gebauer B, et al. Ductoscopy and intraductal vacuum assisted biopsy in women with pathologic nipple discharge. Breast Cancer Res Treat. Oct. 2006;99(3):301-7. Not eligible outcomes. [pmid: 16752074].
1152 Hungness ES, Safa M, Shaughnessy EA, et al. Bilateral synchronous breast cancer: mode of detection and comparison of histologic features between the 2 breasts. Surgery. Oct. 2000;128(4):702-7. Not eligible outcomes. [pmid: 11015105].
1153 Hurd TC, Sneige N, Allen PK, et al. Impact of extensive intraductal component on recurrence and survival in patients with stage I or II breast cancer treated with breast conservation therapy. Ann Surg Oncol. Mar. 1997;4(2):119-24. Not eligible target population. [pmid: 9084847].
1154 Hurley J, Franco S, Gomez-Fernandez C, et al. Breast cancer and human immunodeficiency virus: a report of 20 cases. Clin Breast Cancer. Oct. 2001;2(3):215-20. discussion 21. Not eligible target population. [pmid: 11899415].
1155 Hurst J, Maniar N, Tombarkiewicz J, et al. A novel model of a metastatic human breast tumour xenograft line. Br J Cancer. Aug. 1993;68(2):274-6. Not eligible target population. [pmid: 8394103].
1156 Hussain SK, Altieri A, Sundquist J, et al. Influence of education level on breast cancer risk and survival in Sweden between 1990 and 2004. Int J Cancer. Jan. 1. 2008;122(1):165-9. Not eligible outcomes. [pmid: 17708572].
1157 Hussain SS, Qattan AT, Nirmal MS, et al. Gene expression profiles of the fibroblasts from breast tumors and normal tissue compared with the tumor expression profiles. Saudi Med J. Apr. 2006;27(4):463-9. Not eligible outcomes. [pmid: 16598321].
1158 Hussein MR, Ismael HH. Alterations of p53, Bcl-2, and hMSH2 protein expression in the normal breast, benign proliferative breast disease, in situ and infiltrating ductal breast carcinomas in the upper Egypt. Cancer Biol Ther. Oct. 2004;3(10):983-8. Not eligible outcomes. [pmid: 15467428].
1159 Hussein O, El-Nahhas W, El-Saed A, et al. Video-assisted axillary surgery for cancer: non-randomized comparison with conventional techniques. Breast. Oct. 2007;16(5):513-9. Not eligible target population. [pmid: 17532217].
1160 Huston TL, Pigalarga R, Osborne MP, et al. The influence of additional surgical margins on the total specimen volume excised and the reoperative rate after breast-conserving surgery. Am J Surg. Oct. 2006;192(4):509-12. Not eligible target population. [pmid: 16978962].
1161 Huston TL, Simmons RM. Ductal carcinoma in situ in a 27-year-old woman with McCune-Albright syndrome. Breast J. Sep–Oct. 2004;10(5):440-2. Case Reports. [pmid: 15327499].
1162 Hutter RV. The management of patients with lobular carcinoma in situ of the breast. Cancer. Feb. 1. 1984;53(3 Suppl):798-802. Not eligible outcomes. [pmid: 6692278].
1163 Huynh PT, Parellada JA, de Paredes ES, et al. Dilated duct pattern at mammography. Radiology. Jul. 1997;204(1):137-41. Not eligible outcomes. [pmid: 9205235].
1164 Huzarski T, Lener M, Domagala W, et al. The 3020insC allele of NOD2 predisposes to early-onset breast cancer. Breast Cancer Res Treat. Jan. 2005;89(1):91-3. Not eligible outcomes. [pmid: 15666202].
1165 Hwang ES, Cody HS 3rd. Does the proven benefit of mammography extend to breast cancer patients over age 70. South Med J. Jun. 1998;91(6):522-6. Not eligible target population. [pmid: 9634112].
1166 Hwang ES, DeVries S, Chew KL, et al. Patterns of chromosomal alterations in breast ductal carcinoma in situ. Clin Cancer Res. Aug. 1. 2004;10(15):5160-7. Not eligible outcomes. [pmid: 15297420].
1167 Hwang ES, Esserman L. Neoadjuvant hormonal therapy for ductal carcinoma in situ: trial design and preliminary results. Ann Surg Oncol. Jan. 2004;11(1 Suppl):37S-43S. Not eligible outcomes. [pmid: 15015708].
1168 Hwang ES, McLennan JL, Moore DH, et al. Ductal carcinoma in situ in BRCA mutation carriers. J Clin Oncol. Feb. 20. 2007;25(6):642-7. Not eligible outcomes. [pmid: 17210933].
1169 Hwang TS, Han HS, Hong YC, et al. Prognostic value of combined analysis of cyclin D1 and estrogen receptor status in breast cancer patients. Pathol Int. Feb. 2003;53(2):74-80. Not eligible target population. [pmid: 12588434].
1170 Hyman LJ, Abellera RM. Carcinomatous lymph nodes within breast parenchyma. Arch Surg. Dec. 1974;109(6):759-61. Not eligible target population. [pmid: 4371132].
1171 Iacono C, Facci E, Bortolasi L, et al. Intermediate results of extended pancreaticoduodenectomy. Verona experience. J Hepatobiliary Pancreat Surg. 1999;6(1):74-8. Not eligible target population. [pmid: 10436240].
1172 Ichihara S, Fujimoto T, Hashimoto K, et al. Double immunostaining with p63 and high-molecular-weight cytokeratins distinguishes borderline papillary lesions of the breast. Pathol Int. Mar. 2007;57(3):126-32. Not eligible outcomes. [pmid: 17295644].
1173 Idvall I, Andersson C, Fallenius G, et al. Histopathological and cell biological factors of ductal carcinoma in situ before and after the introduction of mammographic screening. Acta Oncol. 2001;40(5):653-9. Not eligible target population. [pmid: 11669340].
1174 Iglehart JD, Kerns BJ, Huper G, et al. Maintenance of DNA content and erbB-2 alterations in intraductal and invasive phases of mammary cancer. Breast Cancer Res Treat. Jun. 1995;34(3):253-63. Not eligible outcomes. [pmid: 7579490].
1175 Ihrler S, Weiler C, Hirschmann A, et al. Intraductal carcinoma is the precursor of carcinoma ex pleomorphic adenoma and is often associated with dysfunctional p53. Histopathology. Sep. 2007;51(3):362-71. Not eligible target population. [pmid: 17593217].
1176 Iino Y, Sugamata N, Aoyagi H, et al. Nonpalpable breast cancer. Anticancer Res. Sep–Oct. 1994;14(5B):2193-5. Not eligible target population. [pmid: 7840522].
1177 Ikeda DM, Andersson I. Ductal carcinoma in situ: atypical mammographic appearances. Radiology. Sep. 1989;172(3):661-6. Not eligible outcomes. [pmid: 2549563].
1178 Ikeda DM, Birdwell RL, O’Shaughnessy KF, et al. Analysis of 172 subtle findings on prior normal mammograms in women with breast cancer detected at follow-up screening. Radiology. Feb. 2003;226(2):494-503. Not eligible outcomes. [pmid: 12563145].
1179 Ikeda DM, Birdwell RL, O’Shaughnessy KF, et al. Computer-aided detection output on 172 subtle findings on normal mammograms previously obtained in women with breast cancer detected at follow-up screening mammography. Radiology. Mar. 2004;230(3):811-9. Not eligible outcomes. [pmid: 14764891].
1180 Ikeda DM, Helvie MA, Frank TS, et al. Paget disease of the nipple: radiologic-pathologic correlation. Radiology. Oct. 1993;189(1):89-94. Not eligible target population. [pmid: 8396786].
1181 Ikeda O, Nishimura R, Miyayama H, et al. Magnetic resonance evaluation of the presence of an extensive intraductal component in breast cancer. Acta Radiol. Nov. 2004;45(7):721-5. Not eligible outcomes. [pmid: 15624514].
1182 Ikeda T, Jinno H, Shirane M. Chemosensitivity-related genes of breast cancer detected by DNA microarray. Anticancer Res. Jul–Aug. 2007;27(4C):2649-55. Not eligible target population. [pmid: 17695428].
1183 Ikpatt OF, Kuopio T, Ndoma-Egba R, et al. Breast cancer in Nigeria and Finland: epidemiological, clinical and histological comparison. Anticancer Res. Sep–Oct. 2002;22(5):3005-12. Not eligible outcomes. [pmid: 12530033].
1184 Imamura H, Haga S, Shimizu T, et al. Relationship between the morphological and biological characteristics of intraductal components accompanying invasive ductal breast carcinoma and patient age. Breast Cancer Res Treat. Aug. 2000;62(3):177-84. Not eligible target population. [pmid: 11072782].
1185 Inaji H, Koyama H, Motomura K, et al. ErbB-2 protein levels in nipple discharge: role in diagnosis of early breast cancer. Tumour Biol. 1993;14(5):271-8. Not eligible outcomes. [pmid: 7901888].
1186 Indelicato DJ, Grobmyer SR, Newlin H, et al. Delayed breast cellulitis: an evolving complication of breast conservation. Int J Radiat Oncol Biol Phys. Dec. 1. 2006;66(5):1339-46. Not eligible level of evidence. [pmid: 17126205].
1187 Ing S. Dermacase. Paget disease. Can Fam Physician. Jan. 2008;54(1):33. 41. Case Reports. [pmid: 18208950].
1188 Ingle JN, Green SJ, Ahmann DL, et al. Progress report on two clinical trials in women with advanced breast cancer. Trial I: tamoxifen versus tamoxifen plus aminoglutethimide. Trial II: aminoglutethimide in patients with prior tamoxifen exposure. Cancer Res. Aug. 1982;42(8 Suppl):3461s-7s. Not eligible target population. [pmid: 7044529].
1189 Ingle JN, Green SJ, Ahmann DL, et al. Randomized trial of tamoxifen alone or combined with aminoglutethimide and hydrocortisone in women with metastatic breast cancer. J Clin Oncol. Jun. 1986;4(6):958-64. Not eligible target population. [pmid: 3519885].
1190 Ingle JN, Suman VJ, Mailliard JA, et al. Randomized trial of tamoxifen alone or combined with fluoxymesterone as adjuvant therapy in postmenopausal women with resected estrogen receptor positive breast cancer. North Central Cancer Treatment Group Trial 89-30-52. Breast Cancer Res Treat. Jul. 2006;98(2):217-22. Not eligible target population. [pmid: 16538529].
1191 Ingle JN, Tu D, Pater JL, et al. Duration of letrozole treatment and outcomes in the placebo-controlled NCIC CTG MA.17 extended adjuvant therapy trial. Breast Cancer Res Treat. Oct. 2006;99(3):295-300. Not eligible target population. [pmid: 16541302].
1192 Inglis FG, Midgley RD. Subcutaneous mastectomy and immediate prosthetic implantation as an alternative to simple mastectomy. Can J Surg. Jan. 1974;17(1):63-7. Case Reports. [pmid: 4359827].
1193 Inoue T, Tamaki Y, Sato Y, et al. Three-dimensional ultrasound imaging of breast cancer by a real-time intraoperative navigation system. Breast Cancer. 2005;12(2):122-9. Not eligible target population. [pmid: 15858443].
1194 Intra M, Trifiro G, Viale G, et al. Second biopsy of axillary sentinel lymph node for reappearing breast cancer after previous sentinel lymph node biopsy. Ann Surg Oncol. Nov. 2005;12(11):895-9. Not eligible target population. [pmid: 16195833].
1195 Inwang ER, Fentiman IS. Paget’s disease of the nipple. Br J Hosp Med. Dec. 1990;44(6):392-5. Not eligible target population. [pmid: 1964397].
1196 Ioachim E, Kamina S, Demou A, et al. Immunohistochemical localization of metallothionein in human breast cancer in comparison with cathepsin D, stromelysin-1, CD44, extracellular matrix components, P53, Rb, C-erbB-2, EGFR, steroid receptor content and proliferation. Anticancer Res. May–Jun. 1999;19(3A):2133-9. Not eligible outcomes. [pmid: 10470161].
1197 Ioffe OB, Berg WA, Silverberg SG, et al. Mammographic-histopathologic correlation of large-core needle biopsies of the breast. Mod Pathol. Aug. 1998;11(8):721-7. Not eligible outcomes. [pmid: 9720499].
1198 Iqbal J, He G, Biesecker LG, et al. Morphological characterization of the breast in Proteus syndrome complicated by ductal carcinoma in situ. Ann Clin Lab Sci. Autumn. 2006;36(4):469-74. Case Reports. [pmid: 17127737].
1199 Iqbal M, Davies MP, Shoker BS, et al. Subgroups of non-atypical hyperplasia of breast defined by proliferation of oestrogen receptor-positive cells. J Pathol. Mar. 2001;193(3):333-8. Not eligible outcomes. [pmid: 11241412].
1200 Irfan K, Brem RF. Surgical and mammographic follow-up of papillary lesions and atypical lobular hyperplasia diagnosed with stereotactic vacuum-assisted biopsy. Breast J. Jul–Aug. 2002;8(4):230-3. Not eligible target population. [pmid: 12100116].
1201 Irish W, Sherrill B, Cole B, et al. Quality-adjusted survival in a crossover trial of letrozole versus tamoxifen in postmenopausal women with advanced breast cancer. Ann Oncol. Sep. 2005;16(9):1458-62. Not eligible target population. [pmid: 15946978].
1202 Ishag MT, Bashinsky DY, Beliaeva IV, et al. Pathologic findings in reduction mammaplasty specimens. Am J Clin Pathol. Sep. 2003;120(3):377-80. Not eligible outcomes. [pmid: 14502800].
1203 Ishikawa T, Momiyama N, Hamaguchi Y, et al. Evaluation of dynamic studies of MR mammography for the diagnosis of intraductal lesions with nipple discharge. Breast Cancer. 2004;11(3):288-94. Not eligible outcomes. [pmid: 15550848].
1204 Iskaros BE, Sison CP, Hajdu SI. Tenascin patterns of expression in duct carcinoma in situ of the breast. Ann Clin Lab Sci. Jul. 2000;30(3):266-71. Not eligible outcomes. [pmid: 10945566].
1205 Islam QT, Karimeddini MK, Spencer RP, et al. Positive Tc-99m MIBI breast study related to a psoriatic lesion. Clin Nucl Med. May. 2000;25(5):374. Not eligible target population. [pmid: 10795700].
1206 Israeli D, Tartter PI, Brower ST, et al. The significance of family history for patients with carcinoma of the breast. J Am Coll Surg. Jul. 1994;179(1):29-32. Not eligible target population. [pmid: 8019721].
1207 Iveson TJ, Smith IE, Ahern J, et al. Phase I study of the oral nonsteroidal aromatase inhibitor CGS 20267 in healthy postmenopausal women. J Clin Endocrinol Metab. Aug. 1993;77(2):324-31. Not eligible target population. [pmid: 8345035].
1208 Ivy EJ, Sarr MG, Reiman HM. Nonendocrine cancer of the pancreas in patients under age forty years. Surgery. Sep. 1990;108(3):481-7. Not eligible target population. [pmid: 2168585].
1209 Iwamoto M, Shinohara H, Miyamoto A, et al. Prognostic value of tumor-infiltrating dendritic cells expressing CD83 in human breast carcinomas. Int J Cancer. Mar. 10. 2003;104(1):92-7. Not eligible outcomes. [pmid: 12532424].
1210 Jackman RJ, Burbank F, Parker SH, et al. Stereotactic breast biopsy of nonpalpable lesions: determinants of ductal carcinoma in situ underestimation rates. Radiology. Feb. 2001;218(2):497-502. Not eligible outcomes. [pmid: 11161168].
1211 Jackman RJ, Burbank F, Parker SH, et al. Atypical ductal hyperplasia diagnosed at stereotactic breast biopsy: improved reliability with 14-gauge, directional, vacuum-assisted biopsy. Radiology. Aug. 1997;204(2):485-8. Not eligible outcomes. [pmid: 9240540].
1212 Jackman RJ, Nowels KW, Rodriguez-Soto J, et al. Stereotactic, automated, large-core needle biopsy of nonpalpable breast lesions: false-negative and histologic underestimation rates after long-term follow-up. Radiology. Mar. 1999;210(3):799-805. Not eligible outcomes. [pmid: 10207484].
1213 Jackson LC, Camacho F, Levine EA, et al. Patterns of care analysis among women with ductal carcinoma in situ in North Carolina. Am J Surg. Feb. 2008;195(2):164-9. Not eligible outcomes. [pmid: 18096124].
1214 Jackson VP, Dines KA, Bassett LW, et al. Diagnostic importance of the radiographic density of noncalcified breast masses: analysis of 91 lesions. AJR Am J Roentgenol. Jul. 1991;157(1):25-8. Not eligible outcomes. [pmid: 1646563].
1215 Jacobs EJ, Feigelson HS, Bain EB, et al. Polymorphisms in the vascular endothelial growth factor gene and breast cancer in the Cancer Prevention Study II cohort. Breast Cancer Research. 2006;8(2):R22. Not eligible outcomes. [pmid: 16613616].
1216 Jacobs TW, Schnitt SJ, Tan X, et al. Radial scars of the breast and breast carcinomas have similar alterations in expression of factors involved in vascular stroma formation. Hum Pathol. Jan. 2002;33(1):29-38. Not eligible outcomes. [pmid: 11823971].
1217 Jacobson AF, Asad J, Boolbol SK, et al. Do additional shaved margins at the time of lumpectomy eliminate the need for re-excision. Am J Surg. Oct. 2008;196(4):556-8. Not eligible outcomes. [pmid: 18809063].
1218 Jacquemier J, Kurtz JM, Amalric R, et al. An assessment of extensive intraductal component as a risk factor for local recurrence after breast-conserving therapy. Br J Cancer. Jun. 1990;61(6):873-6. Not eligible target population. [pmid: 2164836].
1219 Jaffer S, Bleiweiss IJ. Intraductal papilloma with “comedo-like” necrosis, a diagnostic pitfall. Ann Diagn Pathol. Oct. 2004;8(5):276-9. Not eligible target population. [pmid: 15494933].
1220 Jaffer S, Chen X, Lee L, et al. Pleomorphic solid and cystic papillary carcinoma of the breast: two cases occurring in young women. Ann Diagn Pathol. Jun. 2004;8(3):126-9. Case Reports. [pmid: 15185258].
1221 Jaffer S, Emanuel P, Burstein D, et al. Cytologic findings of spindle cell ductal carcinoma in situ of the breast: a case report. Acta Cytol. May–Jun. 2005;49(3):323-6. Case Reports. [pmid: 15966297].
1222 Jaffer S, Lin R, Bleiweiss IJ, et al. Intraductal carcinoma arising in intraductal papilloma in an axillary lymph node: review of the literature and proposed theories of evolution. Arch Pathol Lab Med. Dec. 2008;132(12):1940-2. Case Reports. [pmid: 19061295].
1223 Jaffer S, Orta L, Sunkara S, et al. Immunohistochemical detection of antiapoptotic protein X-linked inhibitor of apoptosis in mammary carcinoma. Hum Pathol. Jun. 2007;38(6):864-70. Not eligible outcomes. [pmid: 17350670].
1224 Jagadeesan J, Kannan R, Dujon D. Ventricular standstill: a complication of intrapleural anesthesia using bupivacaine in a patient with free transverse rectus abdominus myocutaneous flap breast reconstruction. Ann Plast Surg. Oct. 2007;59(4):445-6. Case Reports. [pmid: 17901739].
1225 Jagsi R, Makris A, Goldberg S, et al. Intra-European differences in the radiotherapeutic management of breast cancer: a survey study. Clin Oncol (R Coll Radiol). Jun. 2006;18(5):369-75. Not eligible target population. [pmid: 16817326].
1226 Jahn H, Osther PJ, Nielsen EH, et al. An electron microscopic study of clinical Paget’s disease of the nipple. APMIS. Sep. 1995;103(9):628-34. Not eligible target population. [pmid: 7488383].
1227 Jaiyesimi IA, Buzdar AU. Adjuvant chemotherapy in high-risk breast cancer patients with ten or more positive lymph nodes. Am J Clin Oncol. Apr. 1992;15(2):180-3. Case Reports. [pmid: 1313203].
1228 Jakesz R, Greil R, Gnant M, et al. Extended adjuvant therapy with anastrozole among postmenopausal breast cancer patients: results from the randomized Austrian Breast and Colorectal Cancer Study Group Trial 6a. J Natl Cancer Inst. Dec. 19. 2007;99(24):1845-53. Not eligible target population. [pmid: 18073378].
1229 Jakubowski DB, Cerussi AE, Bevilacqua F, et al. Monitoring neoadjuvant chemotherapy in breast cancer using quantitative diffuse optical spectroscopy: a case study. J Biomed Opt. Jan–Feb. 2004;9(1):230-8. Case Reports. [pmid: 14715078].
1230 James LA, Mitchell EL, Menasce L, et al. Comparative genomic hybridisation of ductal carcinoma in situ of the breast: identification of regions of DNA amplification and deletion in common with invasive breast carcinoma. Oncogene. Mar. 6. 1997;14(9):1059-65. Not eligible outcomes. [pmid: 9070654].
1231 Jan YJ, Li MC, Ho WL. Collagenous spherulosis presenting as a mass of the breast. Zhonghua Yi Xue Za Zhi (Taipei). Oct. 2002;65(10):494-7. Case Reports. [pmid: 12523815].
1232 Jansen SA, Conzen SD, Fan X, et al. Detection of in situ mammary cancer in a transgenic mouse model: in vitro and in vivo MRI studies demonstrate histopathologic correlation. Phys Med Biol. Oct. 7. 2008;53(19):5481-93. Not eligible target population. [pmid: 18780960].
1233 Jansen SA, Newstead GM, Abe H, et al. Pure ductal carcinoma in situ: kinetic and morphologic MR characteristics compared with mammographic appearance and nuclear grade. Radiology. Dec. 2007;245(3):684-91. Not eligible outcomes. [pmid: 18024450].
1234 Jansen SJ, Stiggelbout AM, Wakker PP, et al. Unstable preferences: a shift in valuation or an effect of the elicitation procedure. Med Decis Making. Jan–Mar. 2000;20(1):62-71. Not eligible target population. [pmid: 10638538].
1235 Janssens JP, Pylyser K, Bekaert J, et al. Biochemical and histochemical analysis of steroid hormone binding sites in human primary breast cancer. Cancer. Jun. 1. 1985;55(11):2600-11. Not eligible outcomes. [pmid: 2986819].
1236 Jarasch ED, Nagle RB, Kaufmann M, et al. Differential diagnosis of benign epithelial proliferations and carcinomas of the breast using antibodies to cytokeratins. Hum Pathol. Mar. 1988;19(3):276-89. Not eligible target population. [pmid: 2450059].
1237 Jarde T, Caldefie-Chezet F, Damez M, et al. Adiponectin and leptin expression in primary ductal breast cancer and in adjacent healthy epithelial and myoepithelial tissue. Histopathology. Oct. 2008;53(4):484-7. Letter. [pmid: 18983614].
1238 Jarvinen TA, Pelto-Huikko M, Holli K, et al. Estrogen receptor beta is coexpressed with ERalpha and PR and associated with nodal status, grade, and proliferation rate in breast cancer. Am J Pathol. Jan. 2000;156(1):29-35. Not eligible outcomes. [pmid: 10623650].
1239 Javid SH, Carlson JW, Garber JE, et al. Breast MRI wire-guided excisional biopsy: specimen size as compared to mammogram wire-guided excisional biopsy and implications for use. Ann Surg Oncol. Dec. 2007;14(12):3352-8. Not eligible outcomes. [pmid: 17849165].
1240 Jenkins JS, Ash S. Metabolism of testosterone by human breast tumours. Lancet. Sep. 9. 1972;2(7776):513-4. Not eligible outcomes. [pmid: 4115571].
1241 Jenkins TM, Young TM, Moniz C, et al. Spastic paresis in Paget’s disease. J R Soc Med. Aug. 2005;98(8):366-8. Case Reports. [pmid: 16055905].
1242 Jenkins V, Shilling V, Fallowfield L, et al. Does hormone therapy for the treatment of breast cancer have a detrimental effect on memory and cognition? A pilot study. Psychooncology. Jan. 2004;13(1):61-6. Not eligible target population. [pmid: 14745746].
1243 Jenkinson AD, Al-Mufti RA, Mohsen Y, et al. Does intraductal breast cancer spread in a segmental distribution? An analysis of residual tumour burden following segmental mastectomy using tumour bed biopsies. Eur J Surg Oncol. Feb. 2001;27(1):21-5. Not eligible target population. [pmid: 11237487].
1244 Jensen HM. On the origin and progression of human breast cancer. Am J Obstet Gynecol. Jun. 1986;154(6):1280-4. Not eligible outcomes. [pmid: 2424309].
1245 Jeschke U, Mylonas I, Kuhn C, et al. Expression of E-cadherin in human ductal breast cancer carcinoma in situ, invasive carcinomas, their lymph node metastases, their distant metastases, carcinomas with recurrence and in recurrence. Anticancer Res. Jul–Aug. 2007;27(4A):1969-74. Not eligible outcomes. [pmid: 17649807].
1246 Jeschke U, Mylonas I, Kunert-Keil C, et al. Expression of glycodelin protein and mRNA in human ductal breast cancer carcinoma in situ, invasive ductal carcinomas, their lymph node and distant metastases, and ductal carcinomas with recurrence. Oncol Rep. Mar. 2005;13(3):413-9. Not eligible outcomes. [pmid: 15706409].
1247 Jeter DD, Vest GR, Buday SJ. Mammographic guidewire localization of nonpalpable breast lesions. Am Surg. Jul. 1991;57(7):431-3. Not eligible outcomes. [pmid: 1647713].
1248 Jewell WR, Krishnan L, Reddy EK, et al. Intraoperative implantation radiation therapy plus lumpectomy for carcinoma of the breast. Arch Surg. Jun. 1987;122(6):687-90. Case Reports. [pmid: 3034194].
1249 Ji J, Hemminki K. Risk for contralateral breast cancers in a population covered by mammography: effects of family history, age at diagnosis and histology. Breast Cancer Res Treat. Oct. 2007;105(2):229-36. Not eligible outcomes. [pmid: 17115107].
1250 Jim HS, Andrykowski MA, Munster PN, et al. Physical symptoms/side effects during breast cancer treatment predict posttreatment distress. Ann Behav Med. Sep–Oct. 2007;34(2):200-8. Not eligible target population. [pmid: 17927558].
1251 Jimenez RE, Bongers S, Bouwman D, et al. Clinicopathologic significance of ductal carcinoma in situ in breast core needle biopsies with invasive cancer. Am J Surg Pathol. Jan. 2000;24(1):123-8. Not eligible outcomes. [pmid: 10632496].
1252 Jimenez RE, Wallis T, Tabasczka P, et al. Determination of Her-2/Neu status in breast carcinoma: comparative analysis of immunohistochemistry and fluorescent in situ hybridization. Mod Pathol. Jan. 2000;13(1):37-45. Not eligible outcomes. [pmid: 10658908].
1253 Jimenez RE, Wallis T, Visscher DW. Centrally necrotizing carcinomas of the breast: a distinct histologic subtype with aggressive clinical behavior. Am J Surg Pathol. Mar. 2001;25(3):331-7. Not eligible target population. [pmid: 11224603].
1254 Jin JS, Cheng TF, Tsai WC, et al. Expression of the serine protease, matriptase, in breast ductal carcinoma of Chinese women: correlation with clinicopathological parameters. Histol Histopathol. Mar. 2007;22(3):305-9. Not eligible outcomes. [pmid: 17163404].
1255 Jirstrom K, Ringberg A, Ferno M, et al. Tissue microarray analyses of G1/S-regulatory proteins in ductal carcinoma in situ of the breast indicate that low cyclin D1 is associated with local recurrence. Br J Cancer. Nov. 17. 2003;89(10):1920-6. Not eligible level of evidence. [pmid: 14612904].
1256 Jo BH, Chun YK. Heterogeneity of invasive ductal carcinoma: proposal for a hypothetical classification. J Korean Med Sci. Jun. 2006;21(3):460-8. Not eligible outcomes. [pmid: 16778390].
1257 Jobsen JJ, Van Der Palen J, Ong F, et al. Differences in outcome for positive margins in a large cohort of breast cancer patients treated with breast-conserving therapy. Acta Oncol. 2007;46(2):172-80. Not eligible target population. [pmid: 17453365].
1258 Joensuu H, Toikkanen S, Klemi PJ. DNA index and S-phase fraction and their combination as prognostic factors in operable ductal breast carcinoma. Cancer. Jul. 15. 1990;66(2):331-40. Not eligible target population. [pmid: 2164437].
1259 Johnell O, Cauley JA, Kulkarni PM, et al. Raloxifene reduces risk of vertebral fractures [corrected] in postmenopausal women regardless of prior hormone therapy. J Fam Pract. Oct. 2004;53(10):789-96. Not eligible outcomes. [pmid: 15469774].
1260 Johnson CH, van Heerden JA, Donohue JH, et al. Oncological aspects of immediate breast reconstruction following mastectomy for malignancy. Arch Surg. Jul. 1989;124(7):819-23. discussion 23-4. Not eligible target populations. [pmid: 2545180].
1261 Johnson JM, Dalton RR, Landercasper J, et al. Image-guided or needle-localized open biopsy of mammographic malignant-appearing microcalcifications. J Am Coll Surg. Dec. 1998;187(6):604-9. Not eligible outcomes. [pmid: 9849733].
1262 Johnson TL, Kini SR. Cytologic and clinicopathologic features of abnormal nipple secretions: 225 cases. Diagn Cytopathol. 1991;7(1):17-22. Not eligible outcomes. [pmid: 1851079].
1263 Johnson-Maddux A, Ashfaq R, Cler L, et al. Reproducibility of cytologic atypia in repeat nipple duct lavage. Cancer. Mar. 15. 2005;103(6):1129-36. Not eligible outcomes. [pmid: 15685620].
1264 Johnston JA, Zwi LJ, Clee CZ. Ductal carcinoma in situ of the breast in a 24 year old woman. Australas Radiol. May. 1992;36(2):150-2. Case Reports. [pmid: 1325770].
1265 Johnston SR, Smith IE, Doody D, et al. Clinical and endocrine effects of the oral aromatase inhibitor vorozole in postmenopausal patients with advanced breast cancer. Cancer Res. Nov. 15. 1994;54(22):5875-81. Not eligible target population. [pmid: 7954417].
1266 Johnstone AJ, Sarkar TK, Hussey JK. Primary hepatocellular carcinoma in a patient with breast carcinoma. Clin Oncol (R Coll Radiol). May. 1991;3(3):180-1. Case Reports. [pmid: 1648953].
1267 Jolles CJ, Smotkin D, Ford KL, et al. Cystic ovarian necrosis complicating tamoxifen therapy for breast cancer in a premenopausal woman. A case report. J Reprod Med. Mar. 1990;35(3):299-300. Case Reports. [pmid: 2157841].
1268 Jolly S, Kestin LL, Goldstein NS, et al. The impact of lobular carcinoma in situ in association with invasive breast cancer on the rate of local recurrence in patients with early-stage breast cancer treated with breast-conserving therapy. Int J Radiat Oncol Biol Phys. Oct. 1. 2006;66(2):365-71. Not eligible target population. [pmid: 16965988].
1269 Jonat W, Howell A, Blomqvist C, et al. A randomised trial comparing two doses of the new selective aromatase inhibitor anastrozole (Arimidex) with megestrol acetate in postmenopausal patients with advanced breast cancer. Eur J Cancer. Mar. 1996;32A(3):404-12. Not eligible target population. [pmid: 8814682].
1270 Jones AL, Powles TJ, Law M, et al. Adjuvant aminoglutethimide for postmenopausal patients with primary breast cancer: analysis at 8 years. J Clin Oncol. Oct. 1992;10(10):1547-52. Not eligible target population. [pmid: 1403034].
1271 Jones C, Damiani S, Wells D, et al. Molecular cytogenetic comparison of apocrine hyperplasia and apocrine carcinoma of the breast. Am J Pathol. Jan. 2001;158(1):207-14. Not eligible target population. [pmid: 11141494].
1272 Jones RE Jr. Mammary Paget’s disease without underlying carcinoma. Am J Dermatopathol. Aug. 1985;7(4):361-5. Not eligible target population. [pmid: 3026196].
1273 Jones RL, Lakhani SR, Ring AE, et al. Pathological complete response and residual DCIS following neoadjuvant chemotherapy for breast carcinoma. Br J Cancer. Feb. 13. 2006;94(3):358-62. Not eligible target population. [pmid: 16421590].
1274 Jones SE. Exemestane as adjuvant treatment of early breast cancer: intergroup exemestane study/tamoxifen exemestane adjuvant multicenter trials. Clin Breast Cancer. Feb. 2006;6(Suppl 2):S41-4. Not eligible target population. [pmid: 16595025].
1275 Jones SE, Cantrell J, Vukelja S, et al. Comparison of menopausal symptoms during the first year of adjuvant therapy with either exemestane or tamoxifen in early breast cancer: report of a Tamoxifen Exemestane Adjuvant Multicenter trial substudy. J Clin Oncol. Oct. 20. 2007;25(30):4765-71. Not eligible target population. [pmid: 17947724].
1276 Jong RA, Yaffe MJ, Skarpathiotakis M, et al. Contrast-enhanced digital mammography: initial clinical experience. Radiology. Sep. 2003;228(3):842-50. Not eligible outcomes. [pmid: 12881585].
1277 Joshi M, Duva-Frissora A, Padmanabhan R, et al. Atypical ductal hyperplasia in stereotactic breast biopsies: enhanced accuracy of diagnosis with the mammotome. Breast J. Jul–Aug. 2001;7(4):207-13. Not eligible outcomes. [pmid: 11678796].
1278 Juraskova I, Butow P, Lopez A, et al. Improving informed consent: pilot of a decision aid for women invited to participate in a breast cancer prevention trial (IBIS-II DCIS). Health Expect. Sep. 2008;11(3):252-62. Not eligible exposure. [pmid: 18816321].
1279 Kaino M, Kondoh S, Okita S, et al. Detection of K-ras and p53 gene mutations in pancreatic juice for the diagnosis of intraductal papillary mucinous tumors. Pancreas. Apr. 1999;18(3):294-9. Not eligible target population. [pmid: 10206488].
1280 Kairouz R, Clarke RA, Marr PJ, et al. ATM protein synthesis patterns in sporadic breast cancer. Mol Pathol. Oct. 1999;52(5):252-6. Not eligible outcomes. [pmid: 10748873].
1281 Kalof AN, Tam D, Beatty B, et al. Immunostaining patterns of myoepithelial cells in breast lesions: a comparison of CD10 and smooth muscle myosin heavy chain. J Clin Pathol. Jun. 2004;57(6):625-9. Not eligible outcomes. [pmid: 15166269].
1282 Kamel EM, Wyss MT, Fehr MK, et al. [18F]-Fluorodeoxyglucose positron emission tomography in patients with suspected recurrence of breast cancer. J Cancer Res Clin Oncol. Mar. 2003;129(3):147-53. Not eligible target population. [pmid: 12712329].
1283 Kamel OW, LeBrun DP, Berry GJ, et al. Warthin-Finkeldey polykaryocytes demonstrate a T-cell immunophenotype. Am J Clin Pathol. Feb. 1992;97(2):179-83. Case Reports. [pmid: 1312298].
1284 Kandalaft PL, Chang KL, Ahn CW, et al. Prognostic significance of immunohistochemical analysis of cathepsin D in low-stage breast cancer. Cancer. May. 1. 1993;71(9):2756-63. Not eligible outcomes. [pmid: 8385566].
1285 Kaneko S, Gerasimova T, Butler WM, et al. The use of FISH on breast core needle samples for the presurgical assessment of HER-2 oncogene status. Exp Mol Pathol. Aug. 2002;73(1):61-6. Not eligible outcomes. [pmid: 12127055].
1286 Kanemaki Y, Kurihara Y, Okamoto K, et al. Ductal carcinoma in situ: correlations between high-resolution magnetic resonance imaging and histopathology. Radiat Med. Jan. 2007;25(1):1-7. Not eligible level of evidence. [pmid: 17225046].
1287 Kang BJ, Jung JI, Park C, et al. Breast MRI findings after modified radical mastectomy and transverse rectus abdominis myocutaneous flap in patients with breast cancer. J Magn Reson Imaging. Jun. 2005;21(6):784-91. Not eligible target population. [pmid: 15906336].
1288 Kang DK, Kim MJ, Jung YS, et al. Clinical application of multidetector row computed tomography in patient with breast cancer. Journal of computer assisted tomography. Jul–Aug. 2008;32(4):583-98. Not eligible target population. [pmid: 18664847].
1289 Kang JH, Kim SJ, Noh DY, et al. Methylation in the p53 promoter is a supplementary route to breast carcinogenesis: correlation between CpG methylation in the p53 promoter and the mutation of the p53 gene in the progression from ductal carcinoma in situ to invasive ductal carcinoma. Lab Invest. Apr. 2001;81(4):573-9. Not eligible outcomes. [pmid: 11304577].
1290 Kang SS, Ko EY, Han BK, et al. Breast US in patients who had microcalcifications with low concern of malignancy on screening mammography. European Journal of Radiology. Aug. 2008;67(2):285-91. Not eligible exposure. [pmid: 17703906].
1291 Kanj SS, Sharara AI, Shpall EJ, et al. Myocardial ischemia associated with high-dose carmustine infusion. Cancer. Nov. 1. 1991;68(9):1910-2. Case Reports. [pmid: 1655228].
1292 Kao GF, Graham JH, Helwig EB. Paget’s disease of the ectopic breast with an underlying intraductal carcinoma: report of a case. J Cutan Pathol. Feb. 1986;13(1):59-66. Not eligible target population. [pmid: 3009569].
1293 Kapenhas-Valdes E, Feldman SM, Cohen JM, et al. Mammary ductoscopy for evaluation of nipple discharge. Ann Surg Oncol. Oct. 2008;15(10):2720-7. Not eligible exposure. [pmid: 18685898].
1294 Kapila K, Pathan SK, Al-Mosawy FA, et al. Fine needle aspiration cytology of breast masses in children and adolescents: experience with 1404 aspirates. Acta Cytol. Nov–Dec. 2008;52(6):681-6. Not eligible outcomes. [pmid: 19068671].
1295 Kaplan C, Matallana R, Wallack MK. The use of state-of-the-art mammography in the detection of nonpalpable breast carcinoma. Am Surg. Jan. 1990;56(1):40-2. Not eligible outcomes. [pmid: 2153010].
1296 Karabakhtsian RG, Johnson R, Sumkin J, et al. The clinical significance of lobular neoplasia on breast core biopsy. Am J Surg Pathol. May. 2007;31(5):717-23. Not eligible outcomes. [pmid: 17460455].
1297 Karayiannakis AJ, Bastounis EA, Chatzigianni EB, et al. Immunohistochemical detection of oestrogen receptors in ductal carcinoma in situ of the breast. Eur J Surg Oncol. Dec. 1996;22(6):578-82. Not eligible outcomes. [pmid: 9005143].
1298 Karayiannakis AJ, Nakopoulou L, Gakiopoulou H, et al. Expression patterns of beta-catenin in in situ and invasive breast cancer. Eur J Surg Oncol. Feb. 2001;27(1):31-6. Not eligible outcomes. [pmid: 11237489].
1299 Karesen R, Jacobsen U, Sauer T, et al. A prospective registration of diagnosis and treatment of breast tumors at the Ulleval hospital 1988-1995. Tidsskr Nor Laegeforen. 1999;10/10; 119(24):3562-6. Language.
1300 Karlsson E, Delle U, Danielsson A, et al. Gene expression variation to predict 10-year survival in lymph-node-negative breast cancer. BMC Cancer. 2008;8:254. Not eligible target population. [pmid: 18778486].
1301 Karnon J, Delea T, Johnston SR, et al. Cost effectiveness of extended adjuvant letrozole in postmenopausal women after adjuvant tamoxifen therapy: the UK perspective. Pharmacoeconomics. 2006;24(3):237-50. Not eligible target population. [pmid: 16519546].
1302 Kasami M, Jensen RA, Simpson JF, et al. Lobulocentricity of breast hypersecretory hyperplasia with cytologic atypia: infrequent association with carcinoma in situ. Am J Clin Pathol. Nov. 2004;122(5):714-20. Not eligible outcomes. [pmid: 15491967].
1303 Kasuga Y, Oohashi T, Nagai N, et al. Primary scirrhous carcinoma of the nipple with symptoms simulating Paget’s disease: report of a case. Surg Today. 1993;23(4):356-9. Not eligible target population. [pmid: 8391348].
1304 Kato M, Oda K, Kubota T, et al. Mucocele-like tumor of the breast caused by ductal carcinoma in situ: a case report. Breast Cancer. 2003;10(2):157-62. Case Reports. [pmid: 12736570].
1305 Kato M, Oda K, Kubota T, et al. Non-palpable and non-invasive ductal carcinoma with bloody nipple discharge successfully resected after cancer spread was accurately diagnosed with three-dimensional computed tomography and galactography. Breast Cancer. 2006;13(4):360-3. Case Reports. [pmid: 17146163].
1306 Katz SJ, Hofer TP, Hawley S, et al. Patterns and correlates of patient referral to surgeons for treatment of breast cancer. J Clin Oncol. Jan. 20. 2007;25(3):271-6. Not eligible outcomes. [pmid: 17235044].
1307 Katz SJ, Lantz PM, Janz NK, et al. Surgeon perspectives about local therapy for breast carcinoma. Cancer. Nov. 1. 2005;104(9):1854-61. Not eligible outcomes. [pmid: 16161056].
1308 Katz SJ, Lantz PM, Janz NK, et al. Patterns and correlates of local therapy for women with ductal carcinoma-in-situ. J Clin Oncol. May. 1. 2005;23(13):3001-7. Not eligible outcomes. [pmid: 15860856].
1309 Katz SJ, Lantz PM, Janz NK, et al. Patient involvement in surgery treatment decisions for breast cancer. J Clin Oncol. Aug. 20. 2005;23(24):5526-33. Not eligible outcomes. [pmid: 16110013].
1310 Katz SJ, Lantz PM, Paredes Y, et al. Breast cancer treatment experiences of Latinas in Los Angeles County. Am J Public Health. Dec. 2005;95(12):2225-30. Not eligible outcomes. [pmid: 16257945].
1311 Katz SJ, Lantz PM, Zemencuk JK. Correlates of surgical treatment type for women with noninvasive and invasive breast cancer. J Womens Health Gend Based Med. Sep. 2001;10(7):659-70. Not eligible outcomes. [pmid: 11571095].
1312 Kauff ND, Brogi E, Scheuer L, et al. Epithelial lesions in prophylactic mastectomy specimens from women with BRCA mutations. Cancer. Apr. 1. 2003;97(7):1601-8. Not eligible outcomes. [pmid: 12655515].
1313 Kaufman CS, Jacobson L, Bachman B, et al. Intraoperative ultrasound facilitates surgery for early breast cancer. Ann Surg Oncol. Dec. 2002;9(10):988-93. Not eligible exposure. [pmid: 12464591].
1314 Kaufman CS, Jacobson L, Bachman B, et al. Intraoperative ultrasonography guidance is accurate and efficient according to results in 100 breast cancer patients. Am J Surg. Oct. 2003;186(4):378-82. Not eligible outcomes. [pmid: 14553854].
1315 Kaufman CS, Rewcastle JC. Cryosurgery for breast cancer. Technol Cancer Res Treat. Apr. 2004;3(2):165-75. Not eligible target population. [pmid: 15059022].
1316 Kaufman SA, Dipetrillo TA, Ruthazer R, et al. MammoSite excision volume as a predictor for residual disease. Cancer. Sep. 1. 2005;104(5):906-12. Not eligible outcomes. [pmid: 16047330].
1317 Kaufmann M, Bajetta E, Dirix LY, et al. Exemestane is superior to megestrol acetate after tamoxifen failure in postmenopausal women with advanced breast cancer: results of a phase III randomized double-blind trial. The Exemestane Study Group. J Clin Oncol. Apr. 2000;18(7):1399-411. Not eligible target population. [pmid: 10735887].
1318 Kaufmann M, Bajetta E, Dirix LY, et al. Exemestane improves survival in metastatic breast cancer: results of a phase III randomized study. Clin Breast Cancer. Sep. 2000;1(Suppl 1):S15-8. Not eligible target population. [pmid: 11970744].
1319 Kaufmann M, Jonat W, Hilfrich J, et al. Improved overall survival in postmenopausal women with early breast cancer after anastrozole initiated after treatment with tamoxifen compared with continued tamoxifen: the ARNO 95 Study. J Clin Oncol. Jul. 1. 2007;25(19):2664-70. Not eligible target population. [pmid: 17563395].
1320 Kawarada Y, Yano T, Yamamoto T, et al. Intraductal mucin-producing tumors of the pancreas. Am J Gastroenterol. May. 1992;87(5):634-8. Case Reports. [pmid: 1317671].
1321 Kawase K, Dimaio DJ, Tucker SL, et al. Paget’s disease of the breast: there is a role for breast-conserving therapy. Ann Surg Oncol. May. 2005;12(5):391-7. Not eligible target population. [pmid: 15915373].
1322 Kawashima H, Matsui O, Suzuki M, et al. Breast cancer in dense breast: detection with contrast-enhanced dynamic MR imaging. J Magn Reson Imaging. Mar. 2000;11(3):233-43. Not eligible outcomes. [pmid: 10739554].
1323 Kaya H, Aribal E, Yegen C. Apocrine differentiation in invasive pleomorphic lobular carcinoma with in situ ductal and lobular apocrine carcinoma: case report. Pathol Oncol Res. 2002;8(2):151-2. Case Reports. [pmid: 12172583].
1324 Kaya H, Erbarut I, Ozkan N, et al. Immunoexpression of HER family, neuregulin, MAPK and AKT in invasive ductal carcinomas of the breast. Eur J Gynaecol Oncol. 2008;29(4):350-6. Not eligible outcomes. [pmid: 18714568].
1325 Kayani N, Bhurgri Y. Ductal carcinoma in situ (DCIS) in Karachi. J Pak Med Assoc. May. 2005;55(5):199-202. Not eligible outcomes. [pmid: 15960285].
1326 Kazakov DV, Suster S, LeBoit PE, et al. Mucinous carcinoma of the skin, primary, and secondary: a clinicopathologic study of 63 cases with emphasis on the morphologic spectrum of primary cutaneous forms: homologies with mucinous lesions in the breast. Am J Surg Pathol. Jun. 2005;29(6):764-82. Case Reports. [pmid: 15897743].
1327 Keatings L, Sinclair J, Wright C, et al. c-erbB-2 oncoprotein expression in mammary and extramammary Paget’s disease: an immunohistochemical study. Histopathology. Sep. 1990;17(3):243-7. Not eligible target population. [pmid: 2173676].
1328 Kelcz F, Furman-Haran E, Grobgeld D, et al. Clinical testing of high-spatial-resolution parametric contrast-enhanced MR imaging of the breast. AJR Am J Roentgenol. Dec. 2002;179(6):1485-92. Not eligible level of evidence. [pmid: 12438042].
1329 Keleher AJ, Langstein HN, Ames FC, et al. Breast cancer in reduction mammaplasty specimens: case reports and guidelines. Breast J. Mar–Apr. 2003;9(2):120-5. Case Reports. [pmid: 12603386].
1330 Kellen E, Putte GV, Van Steen A, et al. Interval cancers in the beginning years of the breast cancer screening programme in the Belgian province of Limburg. Acta Clinica Belgica. May–Jun. 2008;63(3):179-84. Not eligible level of evidence. [pmid: 18714848].
1331 Kelly LM, Hill AD, Kennedy S, et al. Lack of prognostic effect of Cox-2 expression in primary breast cancer on short-term follow-up. Eur J Surg Oncol. Nov. 2003;29(9):707-10. Not eligible outcomes. [pmid: 14602487].
1332 Kelly PM, Davison RS, Bliss E, et al. Macrophages in human breast disease: a quantitative immunohistochemical study. Br J Cancer. Feb. 1988;57(2):174-7. Not eligible outcomes. [pmid: 2833921].
1333 Kelly-Fry E, Morris ST, Jackson VP, et al. Variation of transducer frequency output and receiver band-pass characteristics for improved detection and image characterization of solid breast masses. Ultrasound Med Biol. 1988;14(Suppl 1):143-61. Not eligible outcomes. [pmid: 2847388].
1334 Kennedy S, Merino MJ, Swain SM, et al. The effects of hormonal and chemotherapy on tumoral and nonneoplastic breast tissue. Hum Pathol. Feb. 1990;21(2):192-8. Not eligible target population. [pmid: 2155174].
1335 Kenwright DN, Gaskell D, Wakefield L, et al. Apocrine ductal carcinoma in situ of the breast presenting as a chronic abscess. Aust N Z J Surg. Jan. 1999;69(1):72-5. Case Reports. [pmid: 9932930].
1336 Keohavong P, Gao WM, Mady HH, et al. Analysis of p53 mutations in cells taken from paraffin-embedded tissue sections of ductal carcinoma in situ and atypical ductal hyperplasia of the breast. Cancer Lett. Aug. 20. 2004;212(1):121-30. Not eligible outcomes. [pmid: 15246568].
1337 Kerlikowske K, Grady D, Barclay J, et al. Likelihood ratios for modern screening mammography. Risk of breast cancer based on age and mammographic interpretation. JAMA. Jul. 3. 1996;276(1):39-43. Not eligible outcome. [pmid: 8667537].
1338 Kerlikowske K, Shepherd J, Creasman J, et al. Are breast density and bone mineral density independent risk factors for breast cancer. J Natl Cancer Inst. Mar. 2. 2005;97(5):368-74. Not eligible outcomes. [pmid: 15741573].
1339 Kerlikowske K, Smith-Bindman R, Abraham LA, et al. Breast cancer yield for screening mammographic examinations with recommendation for short-interval follow-up. Radiology. Mar. 2005;234(3):684-92. Not eligible outcomes. [pmid: 15734926].
1340 Kermani IA. Variation of tumor markers in 277 breast cancer cases. Asian Pac J Cancer Prev. Jul–Sep. 2004;5(3):291-3. Not eligible outcomes. [pmid: 15373709].
1341 Kern KA, Rosenberg RJ. Preoperative lymphoscintigraphy during lymphatic mapping for breast cancer: improved sentinel node imaging using subareolar injection of technetium 99m sulfur colloid. J Am Coll Surg. Nov. 2000;191(5):479-89. Not eligible outcomes. [pmid: 11085727].
1342 Kerr JR. Neonatal effects of breast cancer chemotherapy administered during pregnancy. Pharmacotherapy. Mar. 2005;25(3):438-41. Case Reports. [pmid: 15843292].
1343 Kesari AL, Chandrasekhar SD, Rajan B, et al. Clinicopathological significance of tissue homeostasis in Indian breast cancer. Breast Cancer. 2003;10(3):241-8. Not eligible outcomes. [pmid: 12955037].
1344 Keskek M, Kilic M, Ertan T, et al. Bilateral ductal carcinoma in situ of the breast after radiation therapy for Ewing’s sarcoma of the vertebra in a young woman: report of a case. Surg Today. 2008;38(8):739-42. Case Reports. [pmid: 18668319].
1345 Keskek M, Kothari M, Ardehali B, et al. Factors predisposing to cavity margin positivity following conservation surgery for breast cancer. Eur J Surg Oncol. Dec. 2004;30(10):1058-64. Not eligible outcomes. [pmid: 15522551].
1346 Keskikuru R, Bloigu R, Risteli J, et al. Elevated preoperative serum ICTP is a prognostic factor for overall and disease-free survival in breast cancer. Oncol Rep. Nov–Dec. 2002;9(6):1323-7. Not eligible outcomes. [pmid: 12375042].
1347 Kessar P, Perry N, Vinnicombe SJ, et al. How significant is detection of ductal carcinoma in situ in a breast screening programme. Clin Radiol. Sep. 2002;57(9):807-14. Not eligible outcomes. [pmid: 12384106].
1348 Khakpour N, Zager JS, Yen T, et al. The role of ultrasound in the surgical management of patients diagnosed with ductal carcinoma in situ of the breast. Breast J. May–Jun. 2006;12(3):212-5. Not eligible outcomes. [pmid: 16684318].
1349 Khalkhali I, Cutrone JA, Mena IG, et al. Scintimammography: the complementary role of Tc-99m sestamibi prone breast imaging for the diagnosis of breast carcinoma. Radiology. Aug. 1995;196(2):421-6. Not eligible outcomes. [pmid: 7617855].
1350 Khan SA, Wiley EL, Rodriguez N, et al. Ductal lavage findings in women with known breast cancer undergoing mastectomy. J Natl Cancer Inst. Oct. 20. 2004;96(20):1510-7. Not eligible outcomes. [pmid: 15494601].
1351 Khanfir K, Guinebretiere JM, Vanel D, et al. Unusual problems in breast cancer and a rare lung cancer case. Case 2. Aggressive fibromatosis of the chest wall arising near a breast prosthesis. J Clin Oncol. Jun. 1. 2003;21(11):2216-8. Case Reports. [pmid: 12775750].
1352 Khozouz RF, Huq SZ, Perry MC. Radiation-induced liver disease. J Clin Oncol. Oct. 10. 2008;26(29):4844-5. Case Reports. [pmid: 18779598].
1353 Kiaer HW, Kiaer WW, Linell F, et al. Extreme duct papillomatosis of the juvenile breast. Acta Pathol Microbiol Scand [A]. Sep. 1979;87A(5):353-9. Case Reports.
1354 Kikuchi M, Tsunoda-Shimizu H, Kawasaki T, et al. Indications for stereotactically-guided vacuum-assisted breast biopsy for patients with category 3 microcalcifications. Breast Cancer. 2007;14(3):285-91. Not eligible outcomes. [pmid: 17690506].
1355 Kilbride KE, Lee MC, Nees AV, et al. Axillary staging prior to neoadjuvant chemotherapy for breast cancer: predictors of recurrence. Ann Surg Oncol. Nov. 2008;15(11):3252-8. Not eligible target population. [pmid: 18784961].
1356 Killeen JL, Namiki H. DNA analysis of ductal carcinoma in situ of the breast. A comparison with histologic features. Cancer. Dec. 15. 1991;68(12):2602-7. Not eligible outcomes. [pmid: 1657363].
1357 Kiluk JV, Santillan AA, Kaur P, et al. Feasibility of Sentinel Lymph Node Biopsy Through an Inframammary Incision for a Nipple-Sparing Mastectomy. Ann Surg Oncol. 2008. Sep. 27. Not eligible target population.
1358 Kim DH, Yoon DS, Dooley WC, et al. Association of maspin expression with the high histological grade and lymphocyte-rich stroma in early-stage breast cancer. Histopathology. Jan. 2003;42(1):37-42. Not eligible outcomes. [pmid: 12493023].
1359 Kim DJ, Park JY, Lee MH, et al. The role of microsatellite instability at chromosome 11p15.5 in the progression of breast ductal carcinoma. J Korean Med Sci. Oct. 2004;19(5):698-703. Not eligible outcomes. [pmid: 15483347].
1360 Kim do Y, Moon WK, Cho N, et al. MRI of the breast for the detection and assessment of the size of ductal carcinoma in situ. Korean J Radiol. Jan–Feb. 2007;8(1):32-9. Not eligible outcomes. [pmid: 17277561].
1361 Kim HJ, Im YH, Han BK, et al. Accuracy of MRI for estimating residual tumor size after neoadjuvant chemotherapy in locally advanced breast cancer: relation to response patterns on MRI. Acta Oncol. 2007;46(7):996-1003. Not eligible target population. [pmid: 17851879].
1362 Kim MJ, Kim EK, Oh KK, et al. Columnar cell lesions of the breast: mammographic and US features. Eur J Radiol. Nov. 2006;60(2):264-9. Not eligible outcomes. [pmid: 16891081].
1363 Kim MK, Kwon GY, Gong GY. Fine needle aspiration cytology of cystic hypersecretory carcinoma of the breast. A case report. Acta Cytol. May–Jun. 1997;41(3):892-6. Case Reports. [pmid: 9167722].
1364 Kim SH, Ferrante J, Won BR, et al. Barriers to adequate follow-up during adjuvant therapy may be important factors in the worse outcome for Black women after breast cancer treatment. World Journal of Surgical Oncology. 2008;6:26. Not eligible outcomes. [pmid: 18298840].
1365 Kim Y, Pomper J, Goldberg ME. Anesthetic management of the pregnant patient with carcinoma of the breast. J Clin Anesth. Jan–Feb. 1993;5(1):76-8. Case Reports. [pmid: 8382932].
1366 Kimura K, Shinmura K, Hasegawa T, et al. Germline p53 mutation in a patient with multiple primary cancers. Jpn J Clin Oncol. Jul. 2001;31(7):349-51. Case Reports. [pmid: 11518751].
1367 King BL, Tsai SC, Gryga ME, et al. Detection of chromosomal instability in paired breast surgery and ductal lavage specimens by interphase fluorescence in situ hybridization. Clin Cancer Res. Apr. 2003;9(4):1509-16. Not eligible outcomes. [pmid: 12684427].
1368 King EB, Barrett D, Petrakis NL. Cellular composition of the nipple aspirate specimen of breast fluid. II. Abnormal findings. Am J Clin Pathol. Dec. 1975;64(6):739-48. Not eligible outcomes. [pmid: 173176].
1369 King TA, Farr GH Jr, Cederbom GJ, et al. A mass on breast imaging predicts coexisting invasive carcinoma in patients with a core biopsy diagnosis of ductal carcinoma in situ. Am Surg. Sep. 2001;67(9):907-12. Not eligible outcomes. [pmid: 11565774].
1370 King TA, Ganaraj A, Fey JV, et al. Cytokeratin-positive cells in sentinel lymph nodes in breast cancer are not random events: experience in patients undergoing prophylactic mastectomy. Cancer. Sep. 1. 2004;101(5):926-33. Not eligible target population. [pmid: 15329899].
1371 Kinkel K, Gilles R, Feger C, et al. Focal areas of increased opacity in ductal carcinoma in situ of the comedo type: mammographic-pathologic correlation. Radiology. Aug. 1994;192(2):443-6. Not eligible outcomes. [pmid: 8029412].
1372 Kinkel K, Helbich TH, Esserman LJ, et al. Dynamic high-spatial-resolution MR imaging of suspicious breast lesions: diagnostic criteria and interobserver variability. AJR Am J Roentgenol. Jul. 2000;175(1):35-43. Not eligible outcomes. [pmid: 10882243].
1373 Kirstein LJ, Rafferty E, Specht MC, et al. Outcomes of multiple wire localization for larger breast cancers: when can mastectomy be avoided. J Am Coll Surg. Sep. 2008;207(3):342-6. Not eligible exposure. [pmid: 18722938].
1374 Kitchen PR, Cawson JN, Krishnan CM, et al. Axillary dissection and ductal carcinoma in situ of the breast: a change in practice. Aust N Z J Surg. Jun. 2000;70(6):419-22. Not eligible outcomes. [pmid: 10843396].
1375 Kitchen PR, Cawson JN, Moore SE, et al. Margins and outcome of screen-detected breast cancer with extensive in situ component. ANZ J Surg. Jul. 2006;76(7):591-5. Not eligible target population. [pmid: 16813624].
1376 Klauber-Demore N, Calvo BF, Hultman CS, et al. Staged sentinel lymph node biopsy before mastectomy facilitates surgical planning for breast cancer patients. Am J Surg. Oct. 2005;190(4):595-7. Not eligible target population. [pmid: 16164929].
1377 Kleeberg UR, Dowsett M, Carrion RP, et al. A randomised comparison of oestrogen suppression with anastrozole and formestane in postmenopausal patients with advanced breast cancer. Oncology. 1997;54(Suppl 2):19-22. Not eligible target population. [pmid: 9394856].
1378 Kleibl Z, Havranek O, Novotny J, et al. Analysis of CHEK2 FHA domain in Czech patients with sporadic breast cancer revealed distinct rare genetic alterations. Breast Cancer Research & Treatment. Nov. 2008;112(1):159-64. Not eligible outcomes. [pmid: 18058223].
1379 Klem D, Jacobs HK, Jorgensen R, et al. Stereotactic breast biopsy in a community hospital setting. Am Surg. Aug. 1999;65(8):737-40. discussion 40-1. Not eligible outcomes. [pmid: 10432083].
1380 Klika RJ, Callahan KE, Golik KS. Exercise capacity of a breast cancer survivor: a case study. Med Sci Sports Exerc. Oct. 2008;40(10):1711-6. Case Reports. [pmid: 18799979].
1381 Kluttig A, Trocchi P, Heinig A, et al. Reliability and validity of needle biopsy evaluation of breast-abnormalities using the B-categorization--design and objectives of the Diagnosis Optimisation Study (DIOS). BMC Cancer. 2007;7:100. Not eligible outcomes. [pmid: 17570833].
1382 Knoop A, Andreasen PA, Andersen JA, et al. Prognostic significance of urokinase-type plasminogen activator and plasminogen activator inhibitor-1 in primary breast cancer. Br J Cancer. Mar. 1998;77(6):932-40. Not eligible target populations. [pmid: 9528837].
1383 Knopp MV, Weiss E, Sinn HP, et al. Pathophysiologic basis of contrast enhancement in breast tumors. J Magn Reson Imaging. Sep. 1999;10(3):260-6. Not eligible target population. [pmid: 10508285].
1384 Knudsen PJ, Ostergaard J. Cystosarcoma phylloides with lobular and ductal carcinoma in situ. Arch Pathol Lab Med. Sep. 1987;111(9):873-5. Case Reports. [pmid: 2820345].
1385 Ko E, Han W, Lee JW, et al. Scoring system for predicting malignancy in patients diagnosed with atypical ductal hyperplasia at ultrasound-guided core needle biopsy. Breast Cancer Research & Treatment. Nov. 2008;112(1):189-95. Not eligible outcomes. [pmid: 18060577].
1386 Kobayashi M, Ooi A, Oda Y, et al. Protein overexpression and gene amplification of c-erbB-2 in breast carcinomas: a comparative study of immunohistochemistry and fluorescence in situ hybridization of formalin-fixed, paraffin-embedded tissues. Hum Pathol. Jan. 2002;33(1):21-8. Not eligible outcomes. [pmid: 11823970].
1387 Kobayashi TK, Ueda M, Nishino T, et al. Scrape cytology of pemphigus vulgaris of the nipple, a mimicker of Paget’s disease. Diagn Cytopathol. Feb. 1997;16(2):156-9. Not eligible target population. [pmid: 9067110].
1388 Koeberle D, Thuerlimann B. Letrozole as upfront endocrine therapy for postmenopausal women with hormone-sensitive breast cancer: BIG 1-98. Breast Cancer Res Treat. 2007;105(Suppl 1):55-66. Not eligible target population. [pmid: 17912636].
1389 Koerner FC, Oyama T, Maluf H. Morphological observations regarding the origins of atypical cystic lobules (low-grade clinging carcinoma of flat type). Virchows Arch. Oct. 2001;439(4):523-30. Not eligible outcomes. [pmid: 11710639].
1390 Kojima Y, Akiyama T, Saito H, et al. Multifocal intraductal papillary adenocarcinoma of the pancreas: report of a case. Surg Today. 1993;23(5):471-5. Case Reports. [pmid: 8391885].
1391 Kok DL, Chang JH, Erbas B, et al. Urban-rural differences in the management of screen-detected invasive breast cancer and ductal carcinoma in situ in victoria. ANZ J Surg. Nov. 2006;76(11):996-1001. Not eligible outcomes. [pmid: 17054549].
1392 Kokubo M, Mitsumori M, Kanehira K, et al. Results of breast-conserving therapy for ductal carcinoma in situ: the Kyoto University experiences. Breast Cancer. 2001;8(2):153-7. Not eligible level of evidence. [pmid: 11342989].
1393 Kolar Z, Zabransky T, Mattler K, et al. Argyrophilic nucleolar organizer regions in breast cancer: prognostic significance. Cesk Patol. Sep. 1992;28(4):193-200. Not eligible outcomes. [pmid: 1335841].
1394 Kollara A, Kahn HJ, Marks A, et al. Loss of androgen receptor associated protein 70 (ARA70) expression in a subset of HER2-positive breast cancers. Breast Cancer Res Treat. Jun. 2001;67(3):245-53. Not eligible outcomes. [pmid: 11561770].
1395 Kollias J, Ellis IO, Elston CW, et al. Prognostic significance of synchronous and metachronous bilateral breast cancer. World J Surg. Sep. 2001;25(9):1117-24. Not eligible target population. [pmid: 11571945].
1396 Kollias J, Gill PG, Beamond B, et al. Clinical and radiological predictors of complete excision in breast-conserving surgery for primary breast cancer. Aust N Z J Surg. Oct. 1998;68(10):702-6. Not eligible outcomes. [pmid: 9768605].
1397 Kollmorgen DR, Varanasi JS, Edge SB, et al. Paget’s disease of the breast: a 33-year experience. J Am Coll Surg. Aug. 1998;187(2):171-7. Not eligible target population. [pmid: 9704964].
1398 Komatsu K, Nakanishi Y, Seki T, et al. Application of liquid-based preparation to fine needle aspiration cytology in breast cancer. Acta Cytol. Sep–Oct. 2008;52(5):591-6. Not eligible outcomes. [pmid: 18833823].
1399 Komenaka IK, Bauer VP, Schnabel FR, et al. Interpectoral nodes as the initial site of recurrence in breast cancer. Arch Surg. Feb. 2004;139(2):175-8. Not eligible target population. [pmid: 14769576].
1400 Kominsky SL, Argani P, Korz D, et al. Loss of the tight junction protein claudin-7 correlates with histological grade in both ductal carcinoma in situ and invasive ductal carcinoma of the breast. Oncogene. Apr. 3. 2003;22(13):2021-33. Not eligible outcomes. [pmid: 12673207].
1401 Komitowski DD, Hart MM, Janson CP. Chromatin organization and breast cancer prognosis. Two-dimensional and three-dimensional image analysis. Cancer. Aug. 72. 1993;15(4):1239-46. Not eligible outcomes. [pmid: 8393369].
1402 Kondo H, Sugano K, Fukayama N, et al. Detection of K-ras gene mutations at codon 12 in the pancreatic juice of patients with intraductal papillary mucinous tumors of the pancreas. Cancer. Mar. 1. 1997;79(5):900-5. Not eligible target population. [pmid: 9041151].
1403 Kondoh S, Kaino M, Okita S, et al. Detection of Ki-ras and p53 gene mutations in tissue and pancreatic juice from pancreatic adenocarcinomas. J Gastroenterol. Jun. 1998;33(3):390-6. Not eligible target population. [pmid: 9658319].
1404 Kootstra J, Hoekstra-Weebers JE, Rietman H, et al. Quality of life after sentinel lymph node biopsy or axillary lymph node dissection in stage I/II breast cancer patients: a prospective longitudinal study. Annals of Surgical Oncology. Sep. 2008;15(9):2533-41. Not eligible target population. [pmid: 18597146].
1405 Kopans DB. LCIS found at core needle biopsy may not need surgical excision. AJR Am J Roentgenol. Sep. 2008;191(3):W152. author reply W3. Comment. [pmid: 18716082].
1406 Kopans DB, Swann CA, White G, et al. Asymmetric breast tissue. Radiology. Jun. 1989;171(3):639-43. Not eligible outcomes. [pmid: 2541463].
1407 Kordek R. Ductal carcinoma in situ-like structures in metastatic breast carcinoma. Pathol Res Pract. 2005;200:11-12. 831. 4. Case Reports.
1408 Korn RL, Yost AM, May CC, et al. Unexpected focal hypermetabolic activity in the breast: significance in patients undergoing 18F-FDG PET/CT. AJR Am J Roentgenol. Jul. 2006;187(1):81-5. Not eligible outcomes. [pmid: 16794159].
1409 Korourian S, Siegel E, Kieber-Emmons T, et al. Expression analysis of carbohydrate antigens in ductal carcinoma in situ of the breast by lectin histochemistry. BMC Cancer. 2008;8:136. Not eligible outcomes. [pmid: 18479514].
1410 Kosuge T, Makuuchi M, Takayama T, et al. Thickening at the root of the superior mesenteric artery on sonography: evidence of vascular involvement in patients with cancer of the pancreas. AJR Am J Roentgenol. Jan. 1991;156(1):69-72. Not eligible target population. [pmid: 1845788].
1411 Kothari A, Beechey-Newman N, Kulkarni D. Breast duct micro-endoscopy: a study of technique and a morphological classification of endo-luminal lesions. Breast. Jun. 2006;15(3):363-9. Not eligible outcomes. [pmid: 16226462].
1412 Kothari AS, Beechey-Newman N, D’Arrigo C, et al. Breast carcinoma in women age 25 years or less. Cancer. Feb. 1. 2002;94(3):606-14. Case Reports. [pmid: 11857291].
1413 Kothari AS, Beechey-Newman N, Hamed H, et al. Paget disease of the nipple: a multifocal manifestation of higher-risk disease. Cancer. Jul. 1. 2002;95(1):1-7. Not eligible target population. [pmid: 12115309].
1414 Kotwall C, Brinker C, Covington D, et al. Local and national trends over a decade in the surgical treatment of ductal carcinoma in situ. Am J Surg. Dec. 2003;186(6):723-8. discussion 8-9. Not eligible exposure. [pmid: 14672786].
1415 Kouskos E, Gui GP, Mantas D, et al. Wire localisation biopsy of non-palpable breast lesions: reasons for unsuccessful excision. Eur J Gynaecol Oncol. 2006;27(3):262-6. Secondary data anaysis. [pmid: 16800254].
1416 Kovacs A, Dhillon J, Walker RA. Expression of P-cadherin, but not E-cadherin or N-cadherin, relates to pathological and functional differentiation of breast carcinomas. Mol Pathol. Dec. 2003;56(6):318-22. Not eligible outcomes. [pmid: 14645693].
1417 Kovi J, Viola MV. Oral contraceptives and breast histology. JAMA. Feb. 12. 1973;223(7):802. Comment. [pmid: 4346283].
1418 Kowolik JH, Kuhn W, Nahrig J, et al. Detection of micrometastases in sentinel lymph nodes of the breast applying monoclonal antibodies AE1/AE3 to pancytokeratins. Oncol Rep. Jul–Aug. 2000;7(4):745-9. Not eligible target population. [pmid: 10854537].
1419 Koyama H, Inaji H, Yamamoto H, et al. Nucleolar organizer regions in intraductal lesions associated with invasive ductal carcinoma of the breast. Oncology. Mar–Apr. 1993;50(2):116-20. Not eligible outcomes. [pmid: 8383829].
1420 Krajewska M, Krajewski S, Zapata JM, et al. TRAF-4 expression in epithelial progenitor cells. Analysis in normal adult, fetal, and tumor tissues. Am J Pathol. Jun. 1998;152(6):1549-61. Not eligible target population. [pmid: 9626059].
1421 Krassenstein R, Sauter E, Dulaimi E, et al. Detection of breast cancer in nipple aspirate fluid by CpG island hypermethylation. Clin Cancer Res. Jan. 1. 2004;10(1 Pt 1):28-32. Not eligible outcomes. [pmid: 14734448].
1422 Kratzer SS, Cramer HM, Reynolds HE, et al. Fine-needle aspiration cytology of cystic hypersecretory ductal carcinoma in situ of the breast: a case report. Diagn Cytopathol. Mar. 1999;20(3):160-3. Case Reports. [pmid: 10086241].
1423 Kraus-Tiefenbacher U, Bauer L, Scheda A, et al. Intraoperative radiotherapy (IORT) is an option for patients with localized breast recurrences after previous external-beam radiotherapy. BMC Cancer. 2007;7:178. Case reports. [pmid: 17854511].
1424 Kricker A, Armstrong B, Smith C, et al. An audit of breast cancer pathology reporting in Australia in 1995. Br J Cancer. May. 3. 1999:80-4. 563. 8. Not eligible outcomes.
1425 Krishnamurthy S, Sneige N, Thompson PA, et al. Nipple aspirate fluid cytology in breast carcinoma. Cancer. Apr. 25. 2003;99(2):97-104. Not eligible outcomes. [pmid: 12704689].
1426 Krishnan C, Longacre TA. Ductal carcinoma in situ of the breast with osteoclast-like giant cells. Hum Pathol. Mar. 2006;37(3):369-72. Case Reports. [pmid: 16613333].
1427 Krishnan L, Jewell WR, Mansfield CM, et al. Perioperative interstitial irradiation in the conservative management of early breast cancer. Int J Radiat Oncol Biol Phys. Nov. 1987;13(11):1661-5. Not eligible target population. [pmid: 3667373].
1428 Krishnan L, Jewell WR, Mansfield CM, et al. Early-stage breast cancer: local control after conservative surgery and radiation therapy with immediate interstitial boost. Radiology. Apr. 1993;187(1):95-8. Not eligible target population. [pmid: 8383866].
1429 Krishnan L, Jewell WR, Tawfik OW, et al. Breast conservation therapy with tumor bed irradiation alone in a selected group of patients with stage I breast cancer. Breast J. Mar–Apr. 2001;7(2):91-6. Not eligible target population. [pmid: 11328314].
1430 Krishnaraj A, Yankaskas BC, Stearns SC. Screening mammography after breast cancer treatment: patterns in community practice. Breast Cancer Res Treat. May. 2006;97(1):73-80. Not eligible outcomes. [pmid: 16331348].
1431 Kristoffersen Wiberg M, Aspelin P, Sylvan M, et al. Comparison of lesion size estimated by dynamic MR imaging, mammography and histopathology in breast neoplasms. Eur Radiol. Jun. 2003;13(6):1207-12. Not eligible outcomes. [pmid: 12764634].
1432 Krop IE, Sgroi D, Porter DA, et al. HIN-1, a putative cytokine highly expressed in normal but not cancerous mammary epithelial cells. Proc Natl Acad Sci U S A. Aug. 14. 2001;98(17):9796-801. Not eligible target population. [pmid: 11481438].
1433 Krouskop TA, Wheeler TM, Kallel F, et al. Elastic moduli of breast and prostate tissues under compression. Ultrason Imaging. Oct. 1998;20(4):260-74. Not eligible outcomes. [pmid: 10197347].
1434 Kuan SF, Montag AG, Hart J, et al. Differential expression of mucin genes in mammary and extramammary Paget’s disease. Am J Surg Pathol. Dec. 2001;25(12):1469-77. Not eligible target population. [pmid: 11717535].
1435 Kuijper A, Mommers EC, van der Wall E, et al. Histopathology of fibroadenoma of the breast. Am J Clin Pathol. May. 2001;115(5):736-42. Not eligible outcomes. [pmid: 11345838].
1436 Kulkarni S, Patil DB, Diaz LK, et al. COX-2 and PPARgamma expression are potential markers of recurrence risk in mammary duct carcinoma in-situ. BMC Cancer. 2008;8:36. Not eligible level of evidence. [pmid: 18237383].
1437 Kumar AS, Chen DF, Au A, et al. Biologic significance of false-positive magnetic resonance imaging enhancement in the setting of ductal carcinoma in situ. Am J Surg. Oct. 2006;192(4):520-4. Not eligible outcomes. [pmid: 16978965].
1438 Kunju LP, Ding Y, Kleer CG. Tubular carcinoma and grade 1 (well-differentiated) invasive ductal carcinoma: comparison of flat epithelial atypia and other intra-epithelial lesions. Pathol Int. Oct. 2008;58(10):620-5. Not eligible target population. [pmid: 18801081].
1439 Kunju LP, Kleer CG. Significance of flat epithelial atypia on mammotome core needle biopsy: Should it be excised. Hum Pathol. Jan. 2007;38(1):35-41. Not eligible outcomes. [pmid: 17095049].
1440 Kuo WH, Yen AM, Lee PH, et al. Incidence and risk factors associated with bilateral breast cancer in area with early age diagnosis but low incidence of primary breast cancer: analysis of 10-year longitudinal cohort in Taiwan. Breast Cancer Res Treat. Sep. 2006;99(2):221-8. Not eligible target population. [pmid: 16544057].
1441 Kurian KM, Al-Nafussi A. Sarcomatoid/metaplastic carcinoma of the breast: a clinicopathological study of 12 cases. Histopathology. Jan. 2002;40(1):58-64. Not eligible outcomes. [pmid: 11903598].
1442 Kurisu Y, Tsuji M, Akashi K, et al. Composite type of breast carcinoma with endocrine differentiation: a cytological and immunohistochemical study. Pathol Int. Feb. 2004;54(2):105-10. Case Reports. [pmid: 14720141].
1443 Kurniawan ED, Wong MH, Windle I, et al. Predictors of surgical margin status in breast-conserving surgery within a breast screening program. Annals of Surgical Oncology. Sep. 2008;15(9):2542-9. Not eligible outcomes. [pmid: 18618180].
1444 Kuroda H, Ishida F, Nakai M, et al. Basal cytokeratin expression in relation to biological factors in breast cancer. Hum Pathol. Dec. 2008;39(12):1744-50. Not eligible outcomes. [pmid: 18755493].
1445 Kuroda N, Jin YL, Hamauzu T, et al. Consistent lack of CD34-positive stromal cells in the stroma of malignant breast lesions. Histol Histopathol. Jul. 2005;20(3):707-12. Not eligible target population. [pmid: 15944918].
1446 Kurokawa M, Michelangeli VP, Findlay DM. Induction of calcitonin receptor expression by glucocorticoids in T47D human breast cancer cells. J Endocrinol. Aug. 1991;130(2):321-6. Not eligible outcomes. [pmid: 1655943].
1447 Kurosumi M, Takatsuka Y, Watanabe T, et al. Histopathological assessment of anastrozole and tamoxifen as preoperative (neoadjuvant) treatment in postmenopausal Japanese women with hormone receptor-positive breast cancer in the PROACT trial. J Cancer Res Clin Oncol. Jun. 2008;134(6):715-22. Not eligible target population. [pmid: 18075758].
1448 Kurtz JM, Jacquemier J, Amalric R, et al. Risk factors for breast recurrence in premenopausal and postmenopausal patients with ductal cancers treated by conservation therapy. Cancer. Apr. 15. 1990;65(8):1867-78. Not eligible target population. [pmid: 2156607].
1449 Kusama R, Fujimori M, Matsuyama I, et al. Clinicopathological characteristics of atypical cystic duct (ACD) of the breast: assessment of ACD as a precancerous lesion. Pathol Int. Oct. 2000;50(10):793-800. Not eligible outcomes. [pmid: 11107051].
1450 Kuske RR, Bean JM, Garcia DM, et al. Breast conservation therapy for intraductal carcinoma of the breast. Int J Radiat Oncol Biol Phys. Jun. 15. 1993;26(3):391-6. Not eligible level of evidence. [pmid: 8390417].
1451 Kuukasjarvi T, Tanner M, Pennanen S, et al. Genetic changes in intraductal breast cancer detected by comparative genomic hybridization. Am J Pathol. Apr. 1997;150(4):1465-71. Not eligible outcomes. [pmid: 9095001].
1452 Kuusk U, Basco V, Rebbeck P. Comparison of partial and modified radical mastectomy in the community setting--”10 years later”. Can J Surg. Aug. 1992;35(4):383-7. Not eligible target population. [pmid: 1323380].
1453 Kuzmiak CM, Millnamow GA, Qaqish B, et al. Comparison of full-field digital mammography to screen-film mammography with respect to diagnostic accuracy of lesion characterization in breast tissue biopsy specimens. Acad Radiol. Dec. 2002;9(12):1378-82. Not eligible outcomes. [pmid: 12553348].
1454 Kwaepila N, Burns G, Leong AS. Immunohistological localisation of human FAT1 (hFAT) protein in 326 breast cancers. Does this adhesion molecule have a role in pathogenesis?. Pathology. Apr. 2006;38(2):125-31. Not eligible outcomes. [pmid: 16581652].
1455 Kwee AB, Rupa JD. Diagnostic image (396). A woman with an eczematous nipple. Ned Tijdschr Geneeskd. Nov. 15. 2008;152(46):2512-3. Language. [pmid: 19055258].
1456 Kwong A, Hancock SL, Bloom JR, et al. Mammographic screening in women at increased risk of breast cancer after treatment of Hodgkin’s disease. Breast J. Jan–Feb. 2008;14(1):39-48. Not eligible target population. [pmid: 18186864].
1457 Lacomis D, Khoshbin S, Schick RM. MR imaging of paraneoplastic limbic encephalitis. J Comput Assist Tomogr. Jan–Feb. 1990;14(1):115-7. Case Reports. [pmid: 2153718].
1458 Lagios MD. Duct carcinoma in situ. Pathology and treatment. Surg Clin North Am. Aug. 1990;70(4):853-71. Full text was not available. [pmid: 2164715].
1459 Lagios MD, Margolin FR, Westdahl PR, et al. Mammographically detected duct carcinoma in situ. Frequency of local recurrence following tylectomy and prognostic effect of nuclear grade on local recurrence. Cancer. Feb. 15. 1989;63(4):618-24. Not eligible level of evidence. [pmid: 2536582].
1460 Lagios MD, Westdahl PR, Margolin FR, et al. Duct carcinoma in situ. Relationship of extent of noninvasive disease to the frequency of occult invasion, multicentricity, lymph node metastases, and short-term treatment failures. Cancer. Oct. 1. 1982;50(7):1309-14. Not eligible level of evidence. [pmid: 6286091].
1461 Lagios MD, Westdahl PR, Rose MR, et al. Paget’s disease of the nipple. Alternative management in cases without or with minimal extent of underlying breast carcinoma. Cancer. Aug. 1. 1984;54(3):545-51. Not eligible target population. [pmid: 6329506].
1462 Lakhani SR, Collins N, Stratton MR, et al. Atypical ductal hyperplasia of the breast: clonal proliferation with loss of heterozygosity on chromosomes 16q and 17p. J Clin Pathol. Jul. 1995;48(7):611-5. Not eligible outcomes. [pmid: 7560165].
1463 Lamba PS, Bhansali A, Bose SM, et al. Multiple neoplasia in a patient with pituitary acromegaly. J Assoc Physicians India. Apr. 1992;40(4):275-7. Case Reports. [pmid: 1333469].
1464 Lammie GA, Barnes DM, Millis RR, et al. An immunohistochemical study of the presence of c-erbB-2 protein in Paget’s disease of the nipple. Histopathology. Nov. 1989;15(5):505-14. Not eligible target population. [pmid: 2574705].
1465 Lamovec J, Falconieri G, Salviato T, et al. Basaloid carcinoma of the breast: a review of 9 cases, with delineation of a possible clinicopathologic entity. Ann Diagn Pathol. Feb. 2008;12(1):4-11. Case Reports. [pmid: 18164408].
1466 Lampe B, Genz T, Maassen V, et al. Correlation of c-erbB-2 protein expression with histologic grade, lymph node involvement and steroid receptor status in human breast tumors. Arch Gynecol Obstet. 1992;251(1):45-50. Not eligible outcomes. [pmid: 1347986].
1467 Lampejo OT, Barnes DM, Smith P, et al. Evaluation of infiltrating ductal carcinomas with a DCIS component: correlation of the histologic type of the in situ component with grade of the infiltrating component. Semin Diagn Pathol. Aug. 1994;11(3):215-22. Not eligible outcomes. [pmid: 7831533].
1468 Lange M, Kessel I, Kessler E, et al. Intraduct carcinoma of the breast (duct carcinoma in situ). S Afr J Surg. Jun. 1994;32(2):59-61. Not eligible level of evidence. [pmid: 7502173].
1469 Langer I, Marti WR, Guller U, et al. Axillary recurrence rate in breast cancer patients with negative sentinel lymph node (SLN) or SLN micrometastases: prospective analysis of 150 patients after SLN biopsy. Ann Surg. Jan. 2005;241(1):152-8. Not eligible target population. [pmid: 15622003].
1470 Lanitis S, Rice AJ, Vaughan A, et al. Diagnosis and management of male breast cancer. World J Surg. Nov. 2008;32(11):2471-6. Not eligible target population. [pmid: 18787895].
1471 Lantsberg L, Kirshtein B, Koretz M, et al. Role of wire-guided breast biopsy for diagnosis of malignant nonpalpable mammographic lesions. World J Surg. Dec. 1999;23(12):1279-81. Not eligible outcomes. [pmid: 10552121].
1472 Laronga C, Hasson D, Hoover S, et al. Paget’s disease in the era of sentinel lymph node biopsy. Am J Surg. Oct. 2006;192(4):481-3. Not eligible target population. [pmid: 16978954].
1473 Larson PS, de las Morenas A, Cerda SR, et al. Quantitative analysis of allele imbalance supports atypical ductal hyperplasia lesions as direct breast cancer precursors. J Pathol. Jul. 2006;209(3):307-16. Not eligible outcomes. [pmid: 16604511].
1474 Larsson C, Bystrom C, Skoog L, et al. Genomic alterations in human breast carcinomas. Genes Chromosomes Cancer. Sep. 1990;2(3):191-7. Not eligible outcomes. [pmid: 1964080].
1475 LaTrenta LR, Menell JH, Morris EA, et al. Breast lesions detected with MR imaging: utility and histopathologic importance of identification with US. Radiology. Jun. 2003;227(3):856-61. Not eligible outcomes. [pmid: 12773685].
1476 Latta EK, Tjan S, Parkes RK, et al. The role of HER2/neu overexpression/amplification in the progression of ductal carcinoma in situ to invasive carcinoma of the breast. Mod Pathol. Dec. 2002;15(12):1318-25. Not eligible outcomes. [pmid: 12481013].
1477 Launois B, Franci J, Bardaxoglou E, et al. Total pancreatectomy for ductal adenocarcinoma of the pancreas with special reference to resection of the portal vein and multicentric cancer. World J Surg. Jan–Feb. 1993;17(1):122-6. discussion 6-7. Not eligible target population. [pmid: 8383381].
1478 Lavoue V, Graesslin O, Classe JM, et al. Management of lobular neoplasia diagnosed by core needle biopsy: study of 52 biopsies with follow-up surgical excision. Breast. Oct. 2007;16(5):533-9. Not eligible outcomes. [pmid: 17629481].
1479 Lavoue V, Nos C, Clough KB, et al. Simplified technique of radioguided occult lesion localization (ROLL) plus sentinel lymph node biopsy (SNOLL) in breast carcinoma. Annals of Surgical Oncology. Sep. 2008;15(9):2556-61. Not eligible outcomes. [pmid: 18574635].
1480 Laws HL, Kent RB 3rd, Rogers L, et al. Current surgical options in carcinoma of the breast. Ala Med. Mar. 1986;55(9):20-3. Not eligible outcomes. [pmid: 3008546].
1481 Lazaro A, Casinello J, Amoros A, et al. Bilateral inflammatory metachronic ERBB2 (HER2/neu)-positive breast carcinoma: prolonged survival with combined chemotherapy and trastuzumab. Clin Transl Oncol. Sep. 2008;10(9):587-90. Case Reports. [pmid: 18796377].
1482 Le Bouedec G, Gauthier T, Gimbergues P, et al. Axillary recurrence after negative sentinel lymph node biopsy in breast cancer. Presse Med. Nov. 2008;37(11):1685-7. Language. [pmid: 18775635].
1483 Le Doussal V, Tubiana-Hulin M, Friedman S, et al. Prognostic value of histologic grade nuclear components of Scarff-Bloom-Richardson (SBR). An improved score modification based on a multivariate analysis of 1262 invasive ductal breast carcinomas. Cancer. Nov. 9. 1989;64(1):1914-21. Not eligible target population. [pmid: 2551477].
1484 Leal C, Costa I, Fonseca D, et al. Intracystic (encysted) papillary carcinoma of the breast: a clinical, pathological, and immunohistochemical study. Hum Pathol. Oct. 1998;29(10):1097-104. Not eligible target population. [pmid: 9781648].
1485 Leal C, Henrique R, Monteiro P, et al. Apocrine ductal carcinoma in situ of the breast: histologic classification and expression of biologic markers. Hum Pathol. May. 2001;32(5):487-93. Not eligible outcomes. [pmid: 11381366].
1486 Lebrecht A, Buchmann J, Hefler L, et al. Histological category and expression of hormone receptors in ductal carcinoma in situ of the breast. Anticancer Res. May–Jun. 2002;22(3):1909-11. Not eligible outcomes. [pmid: 12168892].
1487 Lebrecht A, Grimm C, Lantzsch T, et al. Monocyte chemoattractant protein-1 serum levels in patients with breast cancer. Tumour Biol. Jan–Apr. 2004;25(1-2):14-7. Not eligible outcomes. [pmid: 15192307].
1488 Lee AH, Happerfield LC, Bobrow LG, et al. Angiogenesis and inflammation in ductal carcinoma in situ of the breast. J Pathol. Feb. 1997;181(2):200-6. Not eligible outcomes. [pmid: 9120726].
1489 Lee AH, Happerfield LC, Millis RR, et al. Inflammatory infiltrate in invasive lobular and ductal carcinoma of the breast. Br J Cancer. Sep. 1996;74(5):796-801. Not eligible outcomes. [pmid: 8795584].
1490 Lee AH, Telfer TP, Millis RR. Metastatic breast carcinoma with appearance resembling micropapillary ductal carcinoma in situ. J Clin Pathol. Apr. 1995;48(4):380-2. Case Reports. [pmid: 7615862].
1491 Lee CG, McCormick B, Mazumdar M, et al. Infiltrating breast carcinoma in patients age 30 years and younger: long term outcome for life, relapse, and second primary tumors. Int J Radiat Oncol Biol Phys. 1992;23(5):969-75. Not eligible target population. [pmid: 1322389].
1492 Lee CH, Carter D, Philpotts LE, et al. Ductal carcinoma in situ diagnosed with stereotactic core needle biopsy: can invasion be predicted. Radiology. Nov. 2000;217(2):466-70. Not eligible outcomes. [pmid: 11058647].
1493 Lee DW, Vallance S. Surgical management of breast cancer in a small peripheral New Zealand hospital. ANZ J Surg. Dec. 2006;76(12):1060-3. Not eligible target population. [pmid: 17199690].
1494 Lee JM, Kaplan JB, Murray MP, et al. Imaging histologic discordance at MRI-guided 9-gauge vacuum-assisted breast biopsy. AJR Am J Roentgenol. Oct. 2007;189(4):852-9. Not eligible exposure. [pmid: 17885056].
1495 Lee JM, Kaplan JB, Murray MP, et al. Complete excision of the MRI target lesion at MRI-guided vacuum-assisted biopsy of breast cancer. AJR Am J Roentgenol. Oct. 2008;191(4):1198-202. Not eligible exposure. [pmid: 18806165].
1496 Lee JM, Kaplan JB, Murray MP, et al. Underestimation of DCIS at MRI-guided vacuum-assisted breast biopsy. AJR Am J Roentgenol. Aug. 2007;189(2):468-74. Not eligible outcomes. [pmid: 17646475].
1497 Lee JM, Kopans DB, McMahon PM, et al. Breast cancer screening in BRCA1 mutation carriers: effectiveness of MR imaging--Markov Monte Carlo decision analysis. Radiology. Mar. 2008;246(3):763-71. Secondary data analysis. [pmid: 18309013].
1498 Lee JS, Fackler MJ, Teo WW, et al. Quantitative promoter hypermethylation profiles of ductal carcinoma in situ in North American and Korean women: Potential applications for diagnosis. Cancer Biol Ther. Sep. 2008;7(9):1398-406. Not eligible outcomes. [pmid: 18769130].
1499 Lee JS, Kim HS, Jung JJ, et al. Mucocele-like tumor of the breast associated with ductal carcinoma in situ and mucinous carcinoma : a case report. J Korean Med Sci. Aug. 2001;16(4):516-8. Case Reports. [pmid: 11511801].
1500 Lee JW, Han W, Ko E, et al. Sonographic lesion size of ductal carcinoma in situ as a preoperative predictor for the presence of an invasive focus. Journal of surgical oncology. Jul. 1. 2008;98(1):15-20. Not eligible outcomes. [pmid: 18459155].
1501 Lee JW, Noh WC, Kim MS, et al. Availability of fine needle aspirates for the assessment of HER2 gene amplification in invasive breast cancer patients. Korean J Lab Med. Oct. 2008;28(5):392-9. Language. [pmid: 18971621].
1502 Lee KJ, Fischer DS, Fappiano AP. Breast carcinoma metastatic to the palatine tonsils. Conn Med. Feb. 1987;51(2):76-9. Case Reports. [pmid: 3030629].
1503 Lee KS, Han BH, Chun YK, et al. Correlation between mammographic manifestations and averaged histopathologic nuclear grade using prognosis-predict scoring system for the prognosis of ductal carcinoma in situ. Clin Imaging. Nov–Dec. 1999;23(6):339-46. Not eligible outcomes. [pmid: 10899414].
1504 Lee L, Pintilie M, Hodgson DC, et al. Screening mammography for young women treated with supradiaphragmatic radiation for Hodgkin’s lymphoma. Ann Oncol. Jan. 2008;19(1):62-7. Not eligible level of evidence. [pmid: 17878177].
1505 Lee SG, Orel SG, Woo IJ, et al. MR imaging screening of the contralateral breast in patients with newly diagnosed breast cancer: preliminary results. Radiology. Mar. 2003;226(3):773-8. Not eligible target population. [pmid: 12601182].
1506 Lee SH, Chaung CR. Mucinous metaplasia of breast carcinoma with macrocystic transformation resembling ovarian mucinous cystadenocarcinoma in a case of synchronous bilateral infiltrating ductal carcinoma. Pathol Int. Sep. 2008;58(9):601-5. Case Reports. [pmid: 18801076].
1507 Lee SH, Chung MA, Chelmow D, et al. Avoidance of adjuvant radiotherapy in selected patients with invasive breast cancer. Ann Surg Oncol. Mar. 2004;11(3):316-21. Not eligible target population. [pmid: 14993028].
1508 Lee SJ, Kim SY, Kim SD. A case of diode laser photocoagulation in the treatment of choroidal metastasis of breast carcinoma. Korean J Ophthalmol. Sep. 2008;22(3):187-9. Case Reports. [pmid: 18784448].
1509 Lee WY. Cytology of abnormal nipple discharge: a cyto-histological correlation. Cytopathology. Feb. 2003;14(1):19-26. Not eligible outcomes. [pmid: 12588306].
1510 Lefkowitz M, Lefkowitz W, Wargotz ES. Intraductal (intracystic) papillary carcinoma of the breast and its variants: a clinicopathological study of 77 cases. Hum Pathol. Aug. 1994;25(8):802-9. Not eligible level of evidence. [pmid: 8056421].
1511 Lehmann U, Hasemeier B, Lilischkis R, et al. Quantitative analysis of promoter hypermethylation in laser-microdissected archival specimens. Lab Invest. Apr. 2001;81(4):635-8. Not eligible outcomes. [pmid: 11304583].
1512 Lehmann U, Langer F, Feist H, et al. Quantitative assessment of promoter hypermethylation during breast cancer development. Am J Pathol. Feb. 2002;160(2):605-12. Not eligible outcomes. [pmid: 11839581].
1513 Leibl S, Regitnig P, Moinfar F. Flat epithelial atypia (DIN 1a, atypical columnar change): an underdiagnosed entity very frequently coexisting with lobular neoplasia. Histopathology. Jun. 2007;50(7):859-65. Not eligible outcomes. [pmid: 17543075].
1514 Leibman AJ, Kruse B. Breast cancer: mammographic and sonographic findings after augmentation mammoplasty. Radiology. Jan. 1990;174(1):195-8. Not eligible outcomes. [pmid: 2152981].
1515 Leibman AJ, Kruse BD. Imaging of breast cancer after augmentation mammoplasty. Ann Plast Surg. Feb. 1993;30(2):111-5. Not eligible outcomes. [pmid: 8387738].
1516 Leidenius MH, Leppanen EA, Tykka HT, et al. The role of Tc99m-sestamibi scintimammography in combination with the triple assessment of primary breast cancer. Eur J Surg Oncol. Mar. 2002;28(2):108-12. Not eligible outcomes. [pmid: 11884044].
1517 Leidenius MH, Ortiz A, Ronka RH, et al. Case report: complete lymphatic staging in breast cancer by lymphoscintigraphy and sentinel node biopsy. Int Surg. Jul–Sep. 2002;87(3):160-3. Case Reports. [pmid: 12403091].
1518 Leifland K, Lundquist H, Lagerstedt U, et al. Comparison of preoperative simultaneous stereotactic fine needle aspiration biopsy and stereotactic core needle biopsy in ductal carcinoma in situ of the breast. Acta Radiol. Mar. 2003;44(2):213-7. Not eligible outcomes. [pmid: 12694110].
1519 Leifland K, Lundquist H, Mare K, et al. Pre-operative simultaneous stereotactic core biopsy and fine-needle aspiration biopsy in the diagnosis of invasive lobular breast carcinoma. Acta Radiol. Jan. 2000;41(1):57-60. Not eligible outcomes. [pmid: 10665872].
1520 Leikola J, Heikkila P, Pamilo M, et al. Predicting invasion in patients with DCIS in the preoperative percutaneous biopsy. Acta Oncol. 2007;46(6):798-802. Not eligible outcomes. [pmid: 17653903].
1521 Leinsinger G, Schlossbauer T, Scherr M, et al. Cluster analysis of signal-intensity time course in dynamic breast MRI: does unsupervised vector quantization help to evaluate small mammographic lesions. Eur Radiol. May. 2006;16(5):1138-46. Full text was not available. [pmid: 16418862].
1522 Lemamy GJ, Sahla ME, Berthe ML, et al. Is the mannose-6-phosphate/insulin-like growth factor 2 receptor coded by a breast cancer suppressor gene?. Advances in Experimental Medicine & Biology. 2008;617:305-10. Not eligible outcomes. [pmid: 18497053].
1523 Lemoine NR, Jain S, Hughes CM, et al. Ki-ras oncogene activation in preinvasive pancreatic cancer. Gastroenterology. Jan. 1992;102(1):230-6. Not eligible target population. [pmid: 1309358].
1524 Leo C, Faber S, Hentschel B, et al. The status of cyclooxygenase-2 expression in ductal carcinoma in situ lesions and invasive breast cancer correlates to cyclooxygenase-2 expression in normal breast tissue. Ann Diagn Pathol. Dec. 2006;10(6):327-32. Not eligible outcomes. [pmid: 17126249].
1525 Lester SC, Bose S, Chen YY, et al. Protocol for the examination of specimens from patients with ductal carcinoma in situ of the breast. Archives of Pathology & Laboratory Medicine. Jan. 2009;133(1):15-25. Guideline. [pmid: 19123730].
1526 Leveque J, Bansard JY, Watier E, et al. Polyamines in human breast cancer and its relations to classical prognostic features: clinical implications. Anticancer Res. May–Jun. 1999;19(3B):2275-9. Not eligible outcomes. [pmid: 10472343].
1527 Lewin AA, Abitbol AA, Schwade JG, et al. Conservative surgery and radiation therapy for early stage breast cancer. Can large trial experiences be reproduced in a community hospital setting?. J Fla Med Assoc. Dec. 1990;77(12):1034-6. Not eligible target population. [pmid: 1963436].
1528 Lewin JM, Isaacs PK, Vance V, et al. Dual-energy contrast-enhanced digital subtraction mammography: feasibility. Radiology. Oct. 2003;229(1):261-8. Not eligible outcomes. [pmid: 12888621].
1529 Lewis JT, Ketterling RP, Halling KC, et al. Analysis of intratumoral heterogeneity and amplification status in breast carcinomas with equivocal (2+) HER-2 immunostaining. Am J Clin Pathol. Aug. 2005;124(2):273-81. Not eligible outcomes. [pmid: 16040300].
1530 Lewis-Jones HG, Whitehouse GH, Leinster SJ. The role of magnetic resonance imaging in the assessment of local recurrent breast carcinoma. Clin Radiol. Mar. 1991;43(3):197-204. Not eligible target population. [pmid: 1849473].
1531 Li CI, Malone KE, Porter PL, et al. Relationship between long durations and different regimens of hormone therapy and risk of breast cancer. JAMA. Jun. 25. 2003;289(24):3254-63. Not eligible outcomes. [pmid: 12824206].
1532 Li CI, Malone KE, Porter PL, et al. The relationship between alcohol use and risk of breast cancer by histology and hormone receptor status among women 65-79 years of age. Cancer Epidemiol Biomarkers Prev. Oct. 2003;12(10):1061-6. Not eligible target population. [pmid: 14578143].
1533 Li H, Chen Q, Zhu R, et al. Clonality analysis of intraductal proliferative lesions using the human androgen receptor assay. Neoplasma. 2007;54(6):490-4. Not eligible outcomes. [pmid: 17949232].
1534 Li J, Orlandi R, White CN, et al. Independent validation of candidate breast cancer serum biomarkers identified by mass spectrometry. Clin Chem. Dec. 2005;51(12):2229-35. Not eligible outcomes. [pmid: 16223889].
1535 Li X, Huang W, Morris EA, et al. Dynamic NMR effects in breast cancer dynamic-contrast-enhanced MRI. Proc Natl Acad Sci U S A. Nov. 18. 2008;105(46):17937-42. Not eligible outcomes. [pmid: 19008355].
1536 Liapis H, Crouch EC, Grosso LE, et al. Expression of parathyroidlike protein in normal, proliferative, and neoplastic human breast tissues. Am J Pathol. Oct. 1993;143(4):1169-78. Not eligible outcomes. [pmid: 8214010].
1537 Liberman L, Bracero N, Morris E, et al. MRI-guided 9-gauge vacuum-assisted breast biopsy: initial clinical experience. AJR Am J Roentgenol. Jul. 2005;185(1):183-93. Not eligible outcomes. [pmid: 15972421].
1538 Liberman L, Bracero N, Vuolo MA, et al. Percutaneous large-core biopsy of papillary breast lesions. AJR Am J Roentgenol. Feb. 1999;172(2):331-7. Not eligible outcomes. [pmid: 9930777].
1539 Liberman L, Cohen MA, Dershaw DD, et al. Atypical ductal hyperplasia diagnosed at stereotaxic core biopsy of breast lesions: an indication for surgical biopsy. AJR Am J Roentgenol. May. 1995;164(5):1111-3. Not eligible outcomes. [pmid: 7717215].
1540 Liberman L, Dershaw DD, Durfee S, et al. Recurrent carcinoma after breast conservation: diagnosis with stereotaxic core biopsy. Radiology. Dec. 1995;197(3):735-8. Not eligible outcomes. [pmid: 7480747].
1541 Liberman L, Dershaw DD, Glassman JR, et al. Analysis of cancers not diagnosed at stereotactic core breast biopsy. Radiology. Apr. 1997;203(1):151-7. Not eligible outcomes. [pmid: 9122384].
1542 Liberman L, Dershaw DD, Rosen PP, et al. Stereotaxic core biopsy of impalpable spiculated breast masses. AJR Am J Roentgenol. Sep. 1995;165(3):551-4. Not eligible outcomes. [pmid: 7645467].
1543 Liberman L, Dershaw DD, Rosen PP, et al. Percutaneous removal of malignant mammographic lesions at stereotactic vacuum-assisted biopsy. Radiology. Mar. 1998;206(3):711-5. Not eligible outcomes. [pmid: 9494489].
1544 Liberman L, Dershaw DD, Rosen PP, et al. Core needle biopsy of synchronous ipsilateral breast lesions: impact on treatment. AJR Am J Roentgenol. Jun. 1996;166(6):1429-32. Not eligible outcomes. [pmid: 8633457].
1545 Liberman L, Drotman M, Morris EA, et al. Imaging-histologic discordance at percutaneous breast biopsy. Cancer. Dec. 15. 2000;89(12):2538-46. Not eligible outcomes. [pmid: 11135213].
1546 Liberman L, Goodstine SL, Dershaw DD, et al. One operation after percutaneous diagnosis of nonpalpable breast cancer: frequency and associated factors. AJR Am J Roentgenol. Mar. 2002;178(3):673-9. Not eligible outcomes. [pmid: 11856696].
1547 Liberman L, Holland AE, Marjan D, et al. Underestimation of atypical ductal hyperplasia at MRI-guided 9-gauge vacuum-assisted breast biopsy. AJR Am J Roentgenol. Mar. 2007;188(3):684-90. Not eligible exposure. [pmid: 17312054].
1548 Liberman L, Kaplan J, Van Zee KJ, et al. Bracketing wires for preoperative breast needle localization. AJR Am J Roentgenol. Sep. 2001;177(3):565-72. Not eligible outcomes. [pmid: 11517048].
1549 Liberman L, Kaplan JB, Morris EA, et al. To excise or to sample the mammographic target: what is the goal of stereotactic 11-gauge vacuum-assisted breast biopsy. AJR Am J Roentgenol. Sep. 2002;179(3):679-83. Case Reports. [pmid: 12185043].
1550 Liberman L, LaTrenta LR, Van Zee KJ, et al. Stereotactic core biopsy of calcifications highly suggestive of malignancy. Radiology. Jun. 1997;203(3):673-7. Not eligible outcomes. [pmid: 9169687].
1551 Liberman L, Morris EA, Benton CL, et al. Probably benign lesions at breast magnetic resonance imaging: preliminary experience in high-risk women. Cancer. Jul. 15. 2003;98(2):377-88. Not eligible outcomes. [pmid: 12872360].
1552 Liberman L, Morris EA, Dershaw DD, et al. Ductal enhancement on MR imaging of the breast. AJR Am J Roentgenol. Aug. 2003;181(2):519-25. Not eligible outcomes. [pmid: 12876038].
1553 Liberman L, Morris EA, Dershaw DD, et al. MR imaging of the ipsilateral breast in women with percutaneously proven breast cancer. AJR Am J Roentgenol. Apr. 2003;180(4):901-10. Not eligible level of evidence. [pmid: 12646427].
1554 Liberman L, Morris EA, Dershaw DD, et al. Fast MRI-guided vacuum-assisted breast biopsy: initial experience. AJR Am J Roentgenol. Nov. 2003;181(5):1283-93. Not eligible exposure. [pmid: 14573421].
1555 Liberman L, Morris EA, Lee MJ, et al. Breast lesions detected on MR imaging: features and positive predictive value. AJR Am J Roentgenol. Jul. 2002;179(1):171-8. Not eligible level of evidence. [pmid: 12076929].
1556 Liberman L, Sama M, Susnik B, et al. Lobular carcinoma in situ at percutaneous breast biopsy: surgical biopsy findings. AJR Am J Roentgenol. Aug. 1999;173(2):291-9. Not eligible target population. [pmid: 10430122].
1557 Liberman L, Smolkin JH, Dershaw DD, et al. Calcification retrieval at stereotactic, 11-gauge, directional, vacuum-assisted breast biopsy. Radiology. Jul. 1998;208(1):251-60. Not eligible outcomes. [pmid: 9646821].
1558 Liberman L, Tornos C, Huzjan R, et al. Is surgical excision warranted after benign, concordant diagnosis of papilloma at percutaneous breast biopsy. AJR Am J Roentgenol. May. 2006;186(5):1328-34. Not eligible target population. [pmid: 16632727].
1559 Liberman L, Vuolo M, Dershaw DD, et al. Epithelial displacement after stereotactic 11-gauge directional vacuum-assisted breast biopsy. AJR Am J Roentgenol. Mar. 1999;172(3):677-81. Not eligible outcomes. [pmid: 10063859].
1560 Lien HC, Lu YS, Cheng AL, et al. Differential expression of glucocorticoid receptor in human breast tissues and related neoplasms. J Pathol. Jul. 2006;209(3):317-27. Not eligible outcomes. [pmid: 16639692].
1561 Ligibel JA, Partridge A, Giobbie-Hurder A, et al. Physical activity behaviors in women with newly diagnosed ductal carcinoma-in-situ. Ann Surg Oncol. Jan. 2009;16(1):106-12. Not eligible outcomes. [pmid: 18953612].
1562 Likaki-Karatza E, Ravazoula P, Androutsopoulos G, et al. Correlation of mammographic appearance and molecular prognostic factors in high-grade breast carcinomas. Eur J Gynaecol Oncol. 2006;27(1):39-41. Not eligible target population. [pmid: 16550966].
1563 Lim CN, Ho BC, Bay BH, et al. Nuclear morphometry in columnar cell lesions of the breast: is it useful. J Clin Pathol. Dec. 2006;59(12):1283-6. Not eligible outcomes. [pmid: 16603646].
1564 Lim M, Bellon JR, Gelman R, et al. A prospective study of conservative surgery without radiation therapy in select patients with Stage I breast cancer. Int J Radiat Oncol Biol Phys. Jul. 15. 2006;65(4):1149-54. Not eligible target population. [pmid: 16750330].
1565 Lin CH, Lee HS, Yu JC. Melanoma of the nipple mimicking Paget’s disease. Dermatol Online J. 2007;13(2):18. Not eligible target population. [pmid: 17498437].
1566 Linda A, Zuiani C, Bazzocchi M, et al. Borderline breast lesions diagnosed at core needle biopsy: can magnetic resonance mammography rule out associated malignancy? Preliminary results based on 79 surgically excised lesions. Breast. Apr. 2008;17(2):125-31. not eligible outcomes. [pmid: 18083514].
1567 Lindemann K, Resau J, Nahrig J, et al. Differential expression of c-Met, its ligand HGF/SF and HER2/neu in DCIS and adjacent normal breast tissue. Histopathology. Jul. 2007;51(1):54-62. Not eligible outcomes. [pmid: 17593080].
1568 Lindfors KK, Kopans DB, Googe PB, et al. Breast cancer metastasis to intramammary lymph nodes. AJR Am J Roentgenol. Jan. 1986;146(1):133-6. Not eligible outcomes. [pmid: 3000154].
1569 Lindholm CE, Andreasson L, Knoos T, et al. Arterial rupture after microwave-induced hyperthermia and radiotherapy. With reference to two patients treated for recurrence in previously operated and irradiated areas. Int J Hyperthermia. May–Jun. 1990;6(3):499-509. Case Reports. [pmid: 2165509].
1570 Linell F, Ljungberg O, Andersson I. Breast carcinoma. Aspects of early stages, progression and related problems. Acta Pathol Microbiol Scand Suppl. 1980:1-233. Comment.
1571 Liney GP, Gibbs P, Hayes C, et al. Dynamic contrast-enhanced MRI in the differentiation of breast tumors: user-defined versus semi-automated region-of-interest analysis. J Magn Reson Imaging. Dec. 1999;10(6):945-9. Not eligible target population. [pmid: 10581507].
1572 Lininger RA, Fujii H, Man YG, et al. Comparison of loss heterozygosity in primary and recurrent ductal carcinoma in situ of the breast. Mod Pathol. Dec. 1998;11(12):1151-9. Not eligible outcomes. [pmid: 9872644].
1573 Lininger RA, Zhuang Z, Man Y, et al. Loss of heterozygosity is detected at chromosomes 1p35-36 (NB), 3p25 (VHL), 16p13 (TSC2/PKD1), and 17p13 (TP53) in microdissected apocrine carcinomas of the breast. Mod Pathol. Dec. 1999;12(12):1083-9. Not eligible outcomes. [pmid: 10619258].
1574 Lipponen PK, Collan Y, Eskelinen MJ. Volume corrected mitotic index (M/V index), mitotic activity index (MAI), and histological grading in breast cancer. Int Surg. Oct–Dec. 1991;76(4):245-9. Not eligible target population. [pmid: 1663917].
1575 Lipton A, Ali SM, Leitzel K, et al. Elevated serum Her-2/neu level predicts decreased response to hormone therapy in metastatic breast cancer. J Clin Oncol. Mar. 15. 2002;20(6):1467-72. Not eligible target population. [pmid: 11896093].
1576 Lipton A, Ali SM, Leitzel K, et al. Serum HER-2/neu and response to the aromatase inhibitor letrozole versus tamoxifen. J Clin Oncol. May. 15. 2003;21(10):1967-72. Not eligible target population. [pmid: 12743150].
1577 Lipton A, Harvey HA, Santen RJ, et al. Randomized trial of aminoglutethimide versus tamoxifen in metastatic breast cancer. Cancer Res. Aug. 1982;42(8 Suppl):3434s-6s. Not eligible target population. [pmid: 7044526].
1578 Lipton A, Leitzel K, Chaudri-Ross HA, et al. Serum TIMP-1 and response to the aromatase inhibitor letrozole versus tamoxifen in metastatic breast cancer. J Clin Oncol. Jun. 1. 2008;26(16):2653-8. Not eligible target population. [pmid: 18443351].
1579 Lipton A, Santen RJ, Harvey HA, et al. A randomized trial of aminoglutethimide +/− estrogen before chemotherapy in advanced breast cancer. Am J Clin Oncol. Feb. 1987;10(1):65-70. Not eligible target population. [pmid: 3548314].
1580 Liu GY, Lu JS, Shen KW, et al. Fiberoptic ductoscopy combined with cytology testing in the patients of spontaneous nipple discharge. Breast Cancer Res Treat. Mar. 2008;108(2):271-7. Not eligible target population. [pmid: 17473979].
1581 Liu J, Baykal A, Fung KM, et al. Human telomerase reverse transcriptase mRNA is highly expressed in normal breast tissues and down-regulated in ductal carcinoma in situ. Int J Oncol. Apr. 2004;24(4):879-84. Not eligible outcomes. [pmid: 15010825].
1582 Liu SM, Chen DR. Signet-ring cell carcinoma of the breast. Pathol Int. Jan. 2000;50(1):67-70. Case Reports. [pmid: 10692181].
1583 Liu YN, Liu Y, Lee HJ, et al. Activated androgen receptor downregulates E-cadherin gene expression and promotes tumor metastasis. Mol Cell Biol. Dec. 2008;28(23):7096-108. Not eligible target population. [pmid: 18794357].
1584 Livasy CA, Perou CM, Karaca G, et al. Identification of a basal-like subtype of breast ductal carcinoma in situ. Hum Pathol. Feb. 2007;38(2):197-204. Not eligible outcomes. [pmid: 17234468].
1585 LiVolsi VA, Kelsey JL, Fischer DB, et al. Effect of age at first childbirth on risk of developing specific histologic subtype of breast cancer. Cancer. May. 1. 1982;49(9):1937-40. Not eligible outcomes. [pmid: 6280850].
1586 Llabres JM. Management of a breast cancer wound in the Hospital of Leman. Soins. Sep. 2008;(728):59-60. Language.
1587 Locke I, Kote-Jarai Z, Jo Fackler M, et al. Gene promoter hypermethylation in ductal lavage fluid from healthy BRCA gene mutation carriers and mutation-negative controls. Breast Cancer Research. 2007;9(1):R20. Not eligible target population. [pmid: 17324252].
1588 Locker AP, Galea MH, Ellis IO, et al. Microdochectomy for single-duct discharge from the nipple. Br J Surg. Jul. 1988;75(7):700-1. Not eligible target population. [pmid: 2843257].
1589 Locker AP, Horrocks C, Gilmour AS, et al. Flow cytometric and histological analysis of ductal carcinoma in situ of the breast. Br J Surg. May. 1990;77(5):564-7. Not eligible outcomes. [pmid: 2162231].
1590 Locker AP, Manhire AR, Stickland V, et al. Mammography in symptomatic breast disease. Lancet. Apr. 22. 1989;1(8643):887-9. Not eligible outcomes. [pmid: 2564959].
1591 Locker GY, Sainsbury JR, Cuzick J. Breast surgery in the ‘Arimidex, Tamoxifen Alone or in Combination’ (ATAC) trial: American women are more likely than women from the United Kingdom to undergo mastectomy. Cancer. Aug. 15. 2004;101(4):735-40. Not eligible target population. [pmid: 15305403].
1592 Loewen MJ, Jennings JA, Sherman SR, et al. Mammographic distance as a predictor of nipple-areola complex involvement in breast cancer. Am J Surg. Mar. 2008;195(3):391-4. discussion 4-5. Not eligible outcomes. [pmid: 18207131].
1593 Loganath A, Peh KL, Gunasegaram R, et al. Comparison of AFP and beta-hCG levels in infiltrating duct mammary carcinoma at different stages of malignancy. Pathology. Jul. 1988;20(3):275-8. Not eligible outcomes. [pmid: 2462707].
1594 Logullo AF, Godoy AB, Mourao-Neto M, et al. Presence of ductal carcinoma in situ confers an improved prognosis for patients with T1N0M0 invasive breast carcinoma. Braz J Med Biol Res. Aug. 2002;35(8):913-9. Not eligible outcomes. [pmid: 12185383].
1595 Lohmann W, Kunzel S. Fluorescence tomographical studies on breast tissue with cancer. Naturwissenschaften. Oct. 1990;77(10):476-8. Case Reports. [pmid: 2177848].
1596 Lomeo AM, Avolio C, Iacobellis G, et al. 5-Fluorouracil cardiotoxicity. Eur J Gynaecol Oncol. 1990;11(3):237-41. Case Reports. [pmid: 2170140].
1597 Lomoschitz FM, Helbich TH, Rudas M, et al. Stereotactic 11-gauge vacuum-assisted breast biopsy: influence of number of specimens on diagnostic accuracy. Radiology. Sep. 2004;232(3):897-903. Not eligible outcomes. [pmid: 15273332].
1598 Londero V, Bazzocchi M, Del Frate C, et al. Locally advanced breast cancer: comparison of mammography, sonography and MR imaging in evaluation of residual disease in women receiving neoadjuvant chemotherapy. Eur Radiol. Aug. 2004;14(8):1371-9. Full text was not available. [pmid: 14986052].
1599 Londero V, Zuiani C, Furlan A, et al. Role of ultrasound and sonographically guided core biopsy in the diagnostic evaluation of ductal carcinoma in situ (DCIS) of the breast. Radiol Med (Torino). Sep. 2007;112(6):863-76. Not eligible outcomes. [pmid: 17891529].
1600 Longatto Filho A, Martins A, Costa SM, et al. VEGFR-3 expression in breast cancer tissue is not restricted to lymphatic vessels. Pathol Res Pract. 2005;201(2):93-9. Not eligible outcomes. [pmid: 15901129].
1601 Longo F. National Conference of Medical Oncology. Controversies in the treatment of breast cancer. Genova. October 28, 2000. Tumori. Nov–Dec. 2000;86(6):A13-8. Language.
1602 Lonning PE, Geisler J, Krag LE, et al. Effects of exemestane administered for 2 years versus placebo on bone mineral density, bone biomarkers, and plasma lipids in patients with surgically resected early breast cancer. J Clin Oncol. Aug. 1. 2005;23(22):5126-37. Not eligible outcomes. [pmid: 15983390].
1603 Loo LW, Ton C, Wang YW, et al. Differential patterns of allelic loss in estrogen receptor-positive infiltrating lobular and ductal breast cancer. Genes Chromosomes Cancer. Dec. 2008;47(12):1049-66. Not eligible target population. [pmid: 18720524].
1604 Losken A, Elwood ET, Styblo TM, et al. The role of reduction mammaplasty in reconstructing partial mastectomy defects. Plast Reconstr Surg. Mar. 2002;109(3):968-75. discussion 76-7. Not eligible exposure. [pmid: 11884818].
1605 Losken A, Schaefer TG, Carlson GW, et al. Immediate endoscopic latissimus dorsi flap: risk or benefit in reconstructing partial mastectomy defects. Ann Plast Surg. Jul. 2004;53(1):1-5. Not eligible exposure. [pmid: 15211189].
1606 Losken A, Styblo TM, Carlson GW, et al. Management algorithm and outcome evaluation of partial mastectomy defects treated using reduction or mastopexy techniques. Ann Plast Surg. Sep. 2007;59(3):235-42. Not eligible exposure. [pmid: 17721207].
1607 Love SM, Gelman RS, Silen W. Sounding board. Fibrocystic “disease” of the breast--a nondisease?. N Engl J Med. Oct. 14. 1982;307(16):1010-4. Not eligible target population. [pmid: 7110289].
1608 Lower EE, Baughman RP. Pulmonary lymphangitic metastasis from breast cancer. Lymphocytic alveolitis is associated with favorable prognosis. Chest. Oct. 1992;102(4):1113-7. Not eligible target population. [pmid: 1327663].
1609 Lowery AJ, Sweeney KJ, Molloy AP, et al. The effect of menopause and hysterectomy on systemic vascular endothelial growth factor in women undergoing surgery for breast cancer. BMC Cancer. 2008;8:279. Not eligible outcomes. [pmid: 18826631].
1610 Lu J, Wei Q, Bondy ML, et al. Promoter polymorphism (−786t>C) in the endothelial nitric oxide synthase gene is associated with risk of sporadic breast cancer in non-Hispanic white women age younger than 55 years. Cancer. Nov. 1. 2006;107(9):2245-53. Not eligible target population. [pmid: 17063466].
1611 Lu ML, Swartz WM. Microsurgery in breast reconstruction using the superior gluteus for free tissue transfer: a case report. J La State Med Soc. Jun. 1988;140(6):43-5. Case Reports. [pmid: 2839616].
1612 Lu YJ, Osin P, Lakhani SR, et al. Comparative genomic hybridization analysis of lobular carcinoma in situ and atypical lobular hyperplasia and potential roles for gains and losses of genetic material in breast neoplasia. Cancer Res. Oct. 15. 1998;58(20):4721-7. Not eligible target population. [pmid: 9788628].
1613 Luboshits G, Shina S, Kaplan O, et al. Elevated expression of the CC chemokine regulated on activation, normal T cell expressed and secreted (RANTES) in advanced breast carcinoma. Cancer Res. Sep. 15. 1999;59(18):4681-7. Not eligible outcomes. [pmid: 10493525].
1614 Lugassy G, Vorst EJ, Varon D, et al. Carcinocythemia. Report of two cases, one simulating a Burkitt lymphoma. Acta Cytol. Mar–Apr. 1990;34(2):265-8. Case Reports. [pmid: 2157324].
1615 Lui CY, Lam HS, Chan LK, et al. Opportunistic breast cancer screening in Hong Kong; a revisit of the Kwong Wah Hospital experience. Hong Kong Med J. Apr. 2007;13(2):106-13. Not eligible outcomes. [pmid: 17406037].
1616 Luke C, Priest K, Roder D. Changes in incidence of in situ and invasive breast cancer by histology type following mammography screening. Asian Pac J Cancer Prev. Jan–Mar. 2006;7(1):69-74. Not eligible outcomes. [pmid: 16629519].
1617 Lundgren S, Gundersen S, Klepp R, et al. Megestrol acetate versus aminoglutethimide for metastatic breast cancer. Breast Cancer Res Treat. Nov. 1989;14(2):201-6. Not eligible target population. [pmid: 2690972].
1618 Lundkvist J, Wilking N, Holmberg S, et al. Cost-effectiveness of exemestane versus tamoxifen as adjuvant therapy for early-stage breast cancer after 2-3 years treatment with tamoxifen in Sweden. Breast Cancer Res Treat. May. 2007;102(3):289-99. Not eligible target population. [pmid: 17033927].
1619 Lundquist K, Kohler S, Rouse RV. Intraepidermal cytokeratin 7 expression is not restricted to Paget cells but is also seen in Toker cells and Merkel cells. Am J Surg Pathol. Feb. 1999;23(2):212-9. Not eligible target population. [pmid: 9989849].
1620 Luoma AA, Scudamore CH, Longley JD. Experience with fine-wire localization breast biopsies for nonpalpable breast lesions detected mammographically. Can J Surg. Sep. 1986;29(5):315-8. Not eligible outcomes. [pmid: 3790211].
1621 Luzzi V, Holtschlag V, Watson MA. Expression profiling of ductal carcinoma in situ by laser capture microdissection and high-density oligonucleotide arrays. Am J Pathol. Jun. 2001;158(6):2005-10. Not eligible outcomes. [pmid: 11395378].
1622 Lynch ED, Ostermeyer EA, Lee MK, et al. Inherited mutations in PTEN that are associated with breast cancer, cowden disease, and juvenile polyposis. Am J Hum Genet. Dec. 1997;61(6):1254-60. Not eligible outcomes. [pmid: 9399897].
1623 Lyng H, Monge OR, Bohler PJ, et al. Temperature distribution in locally advanced breast carcinoma during hyperthermic treatment: relationship to perfusion, vascular density, and histology. Int J Radiat Oncol Biol Phys. Jul. 1991;21(2):423-30. Not eligible target population. [pmid: 1648045].
1624 Lyng H, Monge OR, Bohler PJ, et al. The relevance of tumour and surrounding normal tissue vascular density in clinical hyperthermia of locally advanced breast carcinoma. Int J Radiat Biol. Jul–Aug;. 1991;60(1-2):189-93. Not eligible target population. [pmid: 1677970].
1625 Lyng H, Monge OR, Bohler PJ, et al. Changes in temperatures and thermal doses with fraction number during hyperthermic treatment of locally advanced breast carcinoma. Int J Hyperthermia. Nov–Dec. 1991;7(6):815-25. Not eligible target population. [pmid: 1666900].
1626 Lyng H, Monge OR, Sager EM, et al. Prediction of treatment temperatures in clinical hyperthermia of locally advanced breast carcinoma: the use of contrast enhanced computed tomography. Int J Radiat Oncol Biol Phys. Jun. 15. 1993;26(3):451-7. Not eligible target population. [pmid: 8390419].
1627 Lyng MB, Laenkholm AV, Pallisgaard N, et al. Identification of genes for normalization of real-time RT-PCR data in breast carcinomas. BMC Cancer. 2008;8:20. Not eligible outcomes. [pmid: 18211679].
1628 Ma SY, Shek TW, Au WY. Pagetiform relapse of primary breast lymphoma. Haematologica. Apr. 2004;89(4):EIM03. Not eligible target population. [pmid: 15075106].
1629 Maalej M, Hentati D, Messai T, et al. Breast cancer in Tunisia in 2004: a comparative clinical and epidemiological study. Bull Cancer. Feb. 2008;95(2):E5-9. Not eligible target population. [pmid: 18304901].
1630 Maass N, Nagasaki K, Ziebart M, et al. Expression and regulation of tumor suppressor gene maspin in breast cancer. Clin Breast Cancer. Oct. 2002;3(4):281-7. Not eligible target population. [pmid: 12425757].
1631 MacConmara M, O’Hanlon DM, Kiely MJ, et al. An evaluation of the prognostic significance of vascular endothelial growth factor in node positive primary breast carcinoma. Int J Oncol. Apr. 2002;20(4):717-21. Not eligible outcomes. [pmid: 11894115].
1632 MacGrogan G, Tavassoli FA. Central atypical papillomas of the breast: a clinicopathological study of 119 cases. Virchows Arch. Nov. 2003;443(5):609-17. Not eligible target population. [pmid: 13680220].
1633 Maciejewski R, Madej B, Burdan F, et al. Mammary gland anatomy and the role of mammography and ultrasonography in the early diagnostics of breast cancer. A case report. Folia Morphol (Warsz). Nov. 2003;62(4):519-21. Case Reports. [pmid: 14655157].
1634 MacIntosh RF, Merrimen JL, Barnes PJ. Application of the probabilistic approach to reporting breast fine needle aspiration in males. Acta Cytol. Sep–Oct. 2008;52(5):530-4. Not eligible target population. [pmid: 18833813].
1635 MacKarem G, Roche CA, Hughes KS. The effectiveness of the Gail model in estimating risk for development of breast cancer in women under 40 years of age. Breast J. Jan–Feb. 2001;7(1):34-9. Not eligible target population. [pmid: 11348413].
1636 Mackinnon WB, Barry PA, Malycha PL, et al. Fine-needle biopsy specimens of benign breast lesions distinguished from invasive cancer ex vivo with proton MR spectroscopy. Radiology. Sep. 1997;204(3):661-6. Not eligible level of evidence. [pmid: 9280241].
1637 MacMillan RD, Purushotham AD, Cordiner C, et al. Predicting local recurrence by correlating pre-operative mammographic findings with pathological risk factors in patients with breast cancer. Br J Radiol. May. 1995;68(809):445-9. Not eligible target population. [pmid: 7788226].
1638 Madan AK, Nguyen MT, Wakabayashi MN, et al. Magnification views of mammography decrease biopsy rates. Am Surg. Jul. 2001;67(7):687-9. Not eligible outcomes. [pmid: 11450790].
1639 Madura JA, Wiebke EA, Howard TJ, et al. Mucin-hypersecreting intraductal neoplasms of the pancreas: a precursor to cystic pancreatic malignancies. Surgery. Oct. 1997;122(4):786-92. discussion 92-3. Not eligible target population. [pmid: 9347857].
1640 Maguire HC Jr, Hellman ME, Greene MI, et al. Expression of c-erbB-2 in in situ and in adjacent invasive ductal adenocarcinomas of the female breast. Pathobiology. 1992;60(3):117-21. Not eligible outcomes. [pmid: 1352687].
1641 Mahoney MC, Robinson-Smith TM, Shaughnessy EA. Lobular neoplasia at 11-gauge vacuum-assisted stereotactic biopsy: correlation with surgical excisional biopsy and mammographic follow-up. AJR Am J Roentgenol. Oct. 2006;187(4):949-54. Not eligible outcomes. [pmid: 16985141].
1642 Mahue-Giangreco M, Ursin G, Sullivan-Halley J, et al. Induced abortion, miscarriage, and breast cancer risk of young women. Cancer Epidemiol Biomarkers Prev. Mar. 2003;12(3):209-14. Not eligible target population. [pmid: 12646509].
1643 Mai KT, Perkins DG, Mirsky D. Location and extent of positive resection margins and ductal carcinoma in situ in lumpectomy specimens of ductal breast carcinoma examined with a microscopic three-dimensional view. Breast J. Jan–Feb. 2003;9(1):33-8. Not eligible outcomes. [pmid: 12558668].
1644 Mai KT, Yazdi HM, Burns BF, et al. Pattern of distribution of intraductal and infiltrating ductal carcinoma: a three-dimensional study using serial coronal giant sections of the breast. Hum Pathol. Apr. 2000;31(4):464-74. Not eligible target population. [pmid: 10821494].
1645 Maillard GF, Garey LJ. Immediate reconstruction after subcutaneous mastectomy. Aesthetic Plast Surg. Winter. 1989;13(1):23-6. Not eligible outcomes. [pmid: 2728995].
1646 Mainiero MB, Philpotts LE, Lee CH, et al. Stereotaxic core needle biopsy of breast microcalcifications: correlation of target accuracy and diagnosis with lesion size. Radiology. Mar. 1996;198(3):665-9. Not eligible outcomes. [pmid: 8628852].
1647 Maitra A, Wistuba II, Washington C, et al. High-resolution chromosome 3p allelotyping of breast carcinomas and precursor lesions demonstrates frequent loss of heterozygosity and a discontinuous pattern of allele loss. Am J Pathol. Jul. 2001;159(1):119-30. Not eligible outcomes. [pmid: 11438460].
1648 Majumder SK, Keller MD, Boulos FI, et al. Comparison of autofluorescence, diffuse reflectance, and Raman spectroscopy for breast tissue discrimination. J Biomed Opt. Sep–Oct. 2008;13(5):054009. Not eligible outcomes. [pmid: 19021389].
1649 Makita M, Akiyama F, Gomi N, et al. Endoscopic and histologic findings of intraductal lesions presenting with nipple discharge. Breast J. Sep–Oct. 2006;12(5 Suppl 2):S210-7. Not eligible outcomes. [pmid: 16959004].
1650 Makoske T, Preletz R, Riley L, et al. Long-term outcomes of stereotactic breast biopsies. Am Surg. Dec. 2000;66(12):1104-8. discussion 8-9. Not eligible outcomes. [pmid: 11149580].
1651 Makretsov NA, Hayes M, Carter BA, et al. Stromal CD10 expression in invasive breast carcinoma correlates with poor prognosis, estrogen receptor negativity, and high grade. Mod Pathol. Jan. 2007;20(1):84-9. Not eligible target population. [pmid: 17143263].
1652 Malafa M, Chaudhuri B, Thomford NR, et al. Estrogen receptors in ductal carcinoma in situ of breast. Am Surg. Jul. 1990;56(7):436-9. Not eligible outcomes. [pmid: 2164337].
1653 Malak G, Tapolcsanyi L. Characteristics of Paget’s carcinoma of the nipple and problems of its negligency. Oncology. 1974;30(4):278-93. Not eligible target population. [pmid: 4376591].
1654 Malich A, Boehm T, Facius M, et al. Differentiation of mammographically suspicious lesions: evaluation of breast ultrasound, MRI mammography and electrical impedance scanning as adjunctive technologies in breast cancer detection. Clin Radiol. Apr. 2001;56(4):278-83. Not eligible outcomes. [pmid: 11286578].
1655 Malich A, Bohm T, Facius M, et al. Additional value of electrical impedance scanning: experience of 240 histologically-proven breast lesions. Eur J Cancer. Dec. 2001;37(18):2324-30. Not eligible outcomes. [pmid: 11720824].
1656 Malich A, Marx C, Facius M, et al. Tumour detection rate of a new commercially available computer-aided detection system. Eur Radiol. 2001;11(12):2454-9. Not eligible outcomes. [pmid: 11734939].
1657 Malins DC, Haimanot R. Major alterations in the nucleotide structure of DNA in cancer of the female breast. Cancer Res. Oct. 1. 1991;51(19):5430-2. Not eligible outcomes. [pmid: 1655250].
1658 Malle D, Patakiouta F, Bousoulegas A, et al. Image analysis (DNA ploidy) and expression of c-erb B-2 and p53 in imprint smears of breast cancer. Eur J Gynaecol Oncol. 2003;24(6):531-4. Not eligible outcomes. [pmid: 14658596].
1659 Maloisel F, Dufour P, Bergerat JP, et al. Results of initial doxorubicin, 5-fluorouracil, and cyclophosphamide combination chemotherapy for inflammatory carcinoma of the breast. Cancer. Feb. 15. 1990;65(4):851-5. Not eligible target population. [pmid: 2153434].
1660 Maluf H, Koerner F. Lobular carcinoma in situ and infiltrating ductal carcinoma: frequent presence of DCIS as a precursor lesion. Int J Surg Pathol. Apr. 2001;9(2):127-31. Case Reports. [pmid: 11484500].
1661 Maluf HM, Koerner FC. Solid papillary carcinoma of the breast. A form of intraductal carcinoma with endocrine differentiation frequently associated with mucinous carcinoma. Am J Surg Pathol. Nov. 1995;19(11):1237-44. Not eligible outcomes. [pmid: 7573685].
1662 Mamounas EP, Jeong JH, Wickerham DL, et al. Benefit from exemestane as extended adjuvant therapy after 5 years of adjuvant tamoxifen: intention-to-treat analysis of the National Surgical Adjuvant Breast And Bowel Project B-33 trial. J Clin Oncol. Apr. 20. 2008;26(12):1965-71. Not eligible target population. [pmid: 18332472].
1663 Man YG, Zhang Y, Shen T, et al. cDNA expression profiling reveals elevated gene expression in cell clusters overlying focally disrupted myoepithelial cell layers: implications for breast tumor invasion. Breast Cancer Res Treat. Jan. 2005;89(2):199-208. Not eligible outcomes. [pmid: 15692763].
1664 Manabe T, Ohshio G, Baba N, et al. Factors influencing prognosis and indications for curative pancreatectomy for ductal adenocarcinoma of the head of the pancreas. Int J Pancreatol. Aug–Nov. 1990;7(1-3):187-93. Not eligible target population. [pmid: 1964471].
1665 Manfrin E, Mariotto R, Remo A, et al. Is there still a role for fine-needle aspiration cytology in breast cancer screening? Experience of the Verona Mammographic Breast Cancer Screening Program with real-time integrated radiopathologic activity 1999-2004. Cancer. Apr. 25. 2008;114(2):74-82. Not eligible outcomes. [pmid: 18306357].
1666 Manjer J, Andersson I, Berglund G, et al. Survival of women with breast cancer in relation to smoking. Eur J Surg. Nov. 2000;166(11):852-8. Not eligible target population. [pmid: 11097150].
1667 Mann GJ, Thorne H, Balleine RL, et al. Analysis of cancer risk and BRCA1 and BRCA2 mutation prevalence in the kConFab familial breast cancer resource. Breast Cancer Research. 2006;8:www1-www14. 2006. Not eligible outcomes.
1668 Mannell A. Breast-conserving therapy in breast cancer patients--a 12-year experience. S Afr J Surg. May. 2005;43(2):28-30. discussion, 2. Not eligible target population. [pmid: 16035379].
1669 Manoliu RA, Ooms GH. The accuracy of mammography: an analysis of 655 histologically verified cases. Radiol Clin (Basel). 1977;46(6):422-9. Not eligible outcomes. [pmid: 918299].
1670 Mansour AM, Dinowitz K, Chaljub G, et al. Metastatic lesion of the optic nerve. J Clin Neuroophthalmol. Jun. 1993;13(2):102-4. Case Reports. [pmid: 8393460].
1671 Maor M. Significance of eczema in Paget’s disease of the breast. Eur J Cancer. Jan. 1979;15(1):35-8. Not eligible target population. [pmid: 217690].
1672 Marasa S, Sciancalepore G, Marasa L. Breast cancer less than 1 cm: bio-morphologic characterization with ER, PgR, Ki67, Her-2/Neu, MDV, MAGS, p53, EGF-R. Pathologica. Jun. 2008;100(3):156-61. Language. [pmid: 18841818].
1673 Margenthaler JA, Duke D, Monsees BS, et al. Correlation between core biopsy and excisional biopsy in breast high-risk lesions. Am J Surg. Oct. 2006;192(4):534-7. Not eligible target population. [pmid: 16978969].
1674 Margolin FR, Kaufman L, Jacobs RP, et al. Stereotactic core breast biopsy of malignant calcifications: diagnostic yield of cores with and cores without calcifications on specimen radiographs. Radiology. Oct. 2004;233(1):251-4. Not eligible outcomes. [pmid: 15333764].
1675 Margolin FR, Leung JW, Jacobs RP, et al. Percutaneous imaging-guided core breast biopsy: 5 years’ experience in a community hospital. AJR Am J Roentgenol. Sep. 2001;177(3):559-64. Not eligible outcomes. [pmid: 11517047].
1676 Mariano MN, van den Bosch MA, Daniel BL, et al. Contrast-enhanced MRI of ductal carcinoma in situ: characteristics of a new intensity-modulated parametric mapping technique correlated with histopathologic findings. J Magn Reson Imaging. Oct. 2005;22(4):520-6. Not eligible level of evidence. [pmid: 16142701].
1677 Mariotti C, Feliciotti F, Baldarelli M, et al. Digital stereotactic biopsies for nonpalpable breast lesion. Surg Endosc. Jun. 2003;17(6):911-7. Not eligible outcomes. [pmid: 12632135].
1678 Mariuzzi GM, Mariuzzi L, Mombello A, et al. Quantitative study of ductal breast cancer progression. Morphometric evaluation of phenotypical changes occurring in benign and preinvasive epithelial lesions. Pathol Res Pract. Nov. 1994;190(11):1056-65. Not eligible outcomes. [pmid: 7746739].
1679 Mark HF, Taylor W, Afify A, et al. Stage I and stage II infiltrating ductal carcinoma of the breast analyzed for chromosome 8 copy number using fluorescent in situ hybridization. Pathobiology. 1997;65(4):184-9. Not eligible outcomes. [pmid: 9396041].
1680 Markopoulos C, Chrissochou M, Michailidou A, et al. Effect of exemestane on the lipidemic profile of post-menopausal operable breast cancer patients following 5-7 years of adjuvant tamoxifen: preliminary results of the ATENA substudy. Anticancer Drugs. Sep. 2005;16(8):879-83. Not eligible target population. [pmid: 16096437].
1681 Markopoulos C, Gazet JC. Paget’s disease of the nipple occurring after conservative management of early breast cancer. Eur J Surg Oncol. Feb. 1988;14(1):77-8. Case Reports. [pmid: 2831103].
1682 Markopoulos C, Kouskos E, Phillipidis T. Development of early malignant bilateral breast disease in relation to antidepressant treatment. Acta Chir Belg. Nov–Dec. 2005;105(6):660-1. Case Reports. [pmid: 16438082].
1683 Markopoulos C, Polychronis A, Zobolas V, et al. The effect of exemestane on the lipidemic profile of postmenopausal early breast cancer patients: preliminary results of the TEAM Greek sub-study. Breast Cancer Res Treat. Sep. 2005;93(1):61-6. Not eligible target population. [pmid: 16184460].
1684 Marotta M, D’Armiento FP, Martino G, et al. Glycosaminoglycans in human breast cancer: morphological and biochemical study. Appl Pathol. 1985;3(3):164-9. Not eligible outcomes. [pmid: 3021186].
1685 Marotta M, Martino G, D’Armiento FP, et al. Collagen in human breast cancer: morphological and biochemical study. Appl Pathol. 1985;3(3):170-8. Not eligible outcomes. [pmid: 3021187].
1686 Marotta M, Vecchione R, Martino G, et al. Glycosaminoglycan-enriched extracellular matrix surrounds intraductal carcinoma of human breast: histochemical study. Appl Pathol. 1985;3(3):179-85. Not eligible outcomes. [pmid: 3021188].
1687 Marques AF, Brenda E, Saldiva PH, et al. Capsular hematoma as a late complication in breast reconstruction with silicone gel prostheses. Plast Reconstr Surg. Mar. 1992;89(3):543-5. Case Reports. [pmid: 1311114].
1688 Marret H, Perrotin F, Bougnoux P, et al. Histologic multifocality is predictive of skin recurrences after conserving treatment of stage I and II breast cancers. Breast Cancer Res Treat. Jul. 2001;68(1):1-8. Not eligible target population. [pmid: 11678304].
1689 Marrujo G, Jolly PC, Hall MH. Nonpalpable breast cancer: needle-localized biopsy for diagnosis and considerations for treatment. Am J Surg. May. 1986;151(5):599-602. Not eligible outcomes. [pmid: 3010754].
1690 Marshall JK, Griffith KA, Haffty BG, et al. Conservative management of Paget disease of the breast with radiotherapy: 10- and 15-year results. Cancer. May. 1. 2003;97(9):2142-9. Not eligible target population. [pmid: 12712465].
1691 Martinetti A, Ferrari L, Celio L, et al. The luteinising hormone-releasing hormone analogue triptorelin with or without the aromatase inhibitor formestane in premenopausal breast cancer: effects on bone metabolism markers. J Steroid Biochem Mol Biol. Dec. 1. 2000;75(1):65-73. Not eligible target population. [pmid: 11179910].
1692 Martinetti A, Zilembo N, Ferrari L, et al. Bone turnover markers and insulin-like growth factor components in metastatic breast cancer: results from a randomised trial of exemestane vs megestrol acetate. Anticancer Res. Jul–Aug. 2003;23(4):3485-91. Not eligible target population. [pmid: 12926095].
1693 Martinez-Arribas F, Martin-Garabato E, Zapardiel I, et al. Bax expression in untreated breast cancer: an immunocytometric study of 255 cases. Anticancer Res. Sep–Oct. 2008;28(5A):2595-8. Not eligible outcomes. [pmid: 19035283].
1694 Marucci G, Betts CM, Golouh R, et al. Toker cells are probably precursors of Paget cell carcinoma: a morphological and ultrastructural description. Virchows Arch. Aug. 2002;441(2):117-23. Not eligible target population. [pmid: 12189500].
1695 Masood S, Frykberg ER, McLellan GL, et al. Prospective evaluation of radiologically directed fine-needle aspiration biopsy of nonpalpable breast lesions. Cancer. Oct. 1. 1990;66(7):1480-7. Not eligible outcomes. [pmid: 2169989].
1696 Masood S, Loya A, Khalbuss W. Is core needle biopsy superior to fine-needle aspiration biopsy in the diagnosis of papillary breast lesions. Diagn Cytopathol. Jun. 2003;28(6):329-34. Not eligible target population. [pmid: 12768640].
1697 Masukawa T, Kuzma JF, Straumfjord JV. Cytologic detection of early Paget’s disease of breast with improved cellular collection method. Acta Cytol. May–Jun. 1975;19(3):274-8. Not eligible target population. [pmid: 167540].
1698 Masunaga S, Hiraoka M, Takahashi M, et al. Clinical results of thermoradiotherapy for locally advanced and/or recurrent breast cancer--comparison of results with radiotherapy alone. Int J Hyperthermia. May–Jun. 1990;6(3):487-97. Not eligible target population. [pmid: 2165508].
1699 Mathelin C, Salvador S, Bekaert V, et al. A new intraoperative gamma camera for the sentinel lymph node procedure in breast cancer. Anticancer Res. Sep–Oct. 2008;28(5B):2859-64. Not eligible outcomes. [pmid: 19031925].
1700 Mathers ME, Shrimankar J. Lobular Neoplasia within a Myoid Hamartoma of the Breast. Breast J. Jan–Feb. 2004;10(1):58-9. Case Reports. [pmid: 14717763].
1701 Matsunaga T, Kawakami Y, Namba K, et al. Intraductal biopsy for diagnosis and treatment of intraductal lesions of the breast. Cancer. Nov. 15. 2004;101(10):2164-9. Not eligible outcomes. [pmid: 15484220].
1702 Matsuo K, Fukutomi T, Akashi-Tanaka S, et al. Histological grade, p53, HER2 and hormone receptor status of synchronous bilateral breast carcinoma. Breast Cancer. 2002;9(2):127-33. Not eligible outcomes. [pmid: 12016392].
1703 Matsuo K, Fukutomi T, Watanabe T, et al. Concordance in pathological response to neoadjuvant chemotherapy between invasive and noninvasive components of primary breast carcinomas. Breast Cancer. 2002;9(1):75-81. Not eligible target population. [pmid: 12196726].
1704 Mauriac L, Keshaviah A, Debled M, et al. Predictors of early relapse in postmenopausal women with hormone receptor-positive breast cancer in the BIG 1-98 trial. Ann Oncol. May. 2007;18(5):859-67. Not eligible target population. [pmid: 17301074].
1705 Maxhimer JB, Quiros RM, Stewart R, et al. Heparanase-1 expression is associated with the metastatic potential of breast cancer. Surgery. Aug. 2002;132(2):326-33. Not eligible outcomes. [pmid: 12219030].
1706 Mayr NA, Staples JJ, Robinson RA, et al. Intraductal breast carcinoma: initial results of a morphometric study using computerized digital image analysis. Clin Oncol (R Coll Radiol). Mar. 1990;2(2):66-70. Not eligible outcomes. [pmid: 2175642].
1707 Mayr NA, Staples JJ, Robinson RA, et al. Morphometric studies in intraductal breast carcinoma using computerized image analysis. Cancer. Jun. 1. 1991;67(11):2805-12. Not eligible outcomes. [pmid: 1851048].
1708 Mayun AA, Pindiga UH, Babayo UD. Pattern of histopathological diagnosis of breast lesions in Gombe, Nigeria. Niger J Med. Apr–Jun. 2008;17(2):159-62. Not eligible target population. [pmid: 18686831].
1709 Mazouni C, Peintinger F, Wan-Kau S, et al. Residual ductal carcinoma in situ in patients with complete eradication of invasive breast cancer after neoadjuvant chemotherapy does not adversely affect patient outcome. J Clin Oncol. Jul. 1. 2007;25(19):2650-5. Not eligible target population. [pmid: 17602071].
1710 Mazouni C, Rouzier R, Balleyguier C, et al. Specimen radiography as predictor of resection margin status in non-palpable breast lesions. Clin Radiol. Sep. 2006;61(9):789-96. Not eligible outcomes. [pmid: 16905388].
1711 McCann J, Treasure P, Duffy S. Modelling the impact of detecting and treating ductal carcinoma in situ in a breast screening programme. J Med Screen. 2004;11(3):117-25. Not eligible outcomes. [pmid: 15333269].
1712 McColl I. Reconstruction of the breast with omentum after subcutaneous mastectomy. Lancet. Jan. 20. 1979;1(8108):134-5. Case Reports. [pmid: 84155].
1713 McCormick B, Rosen PP, Kinne D, et al. Duct carcinoma in situ of the breast: an analysis of local control after conservation surgery and radiotherapy. Int J Radiat Oncol Biol Phys. Jul. 1991;21(2):289-92. Not eligible level of evidence. [pmid: 1648042].
1714 McCready DR, Chapman JA, Hanna WM, et al. Factors affecting distant disease-free survival for primary invasive breast cancer: use of a log-normal survival model. Ann Surg Oncol. Jul. 2000;7(6):416-26. Not eligible target population. [pmid: 10894137].
1715 McCreery BR, Frankl G, Frost DB. An analysis of the results of mammographically guided biopsies of the breast. Surg Gynecol Obstet. Mar. 1991;172(3):223-6. Not eligible outcomes. [pmid: 1847244].
1716 McCulley SJ, Durani P, Macmillan RD. Therapeutic mammaplasty for centrally located breast tumors. Plast Reconstr Surg. Feb. 2006;117(2):366-73. Not eligible outcomes. [pmid: 16462314].
1717 McCulley SJ, Macmillan RD. Therapeutic mammaplasty--analysis of 50 consecutive cases. Br J Plast Surg. Oct. 2005;58(7):902-7. Not eligible target population. [pmid: 16043153].
1718 McDonald MW, Godette KD, Butker EK, et al. Long-term outcomes of IMRT for breast cancer: a single-institution cohort analysis. International journal of radiation oncology, biology, physics. Nov. 15. 2008;72(4):1031-40. Not eligible level of evidence.
1719 McKinney CD, Frierson HF Jr, Fechner RE, et al. Pathologic findings in nonpalpable invasive breast cancer. Am J Surg Pathol. Jan. 1992;16(1):33-6. Not eligible outcomes. [pmid: 1309412].
1720 McLaren BK, Gobbi H, Schuyler PA, et al. Immunohistochemical expression of estrogen receptor in enlarged lobular units with columnar alteration in benign breast biopsies: a nested case-control study. Am J Surg Pathol. Jan. 2005;29(1):105-8. Not eligible outcomes. [pmid: 15613861].
1721 McPhail G, Wilson S. Women’s experience of breast conserving treatment for breast cancer. Eur J Cancer Care (Engl). Sep. 2000;9(3):144-50. Not eligible outcomes. [pmid: 11881723].
1722 McWhorter WP, Mayer WJ. Black/white differences in type of initial breast cancer treatment and implications for survival. Am J Public Health. Dec. 1987;77(12):1515-7. Not eligible target population. [pmid: 2823619].
1723 Mechera R, Viehl CT, Oertli D. Factors predicting in-breast tumor recurrence after breast-conserving surgery. Breast Cancer Res Treat. 2008. Sep. 25. Not eligible target population.
1724 Meeuwis C, Peters NH, Mali WP, et al. Targeting difficult accessible breast lesions: MRI-guided needle localization using a freehand technique in a 3.0 T closed bore magnet. Eur J Radiol. May. 2007;62(2):283-8. Not eligible outcomes. [pmid: 17218074].
1725 Megha T, Ferrari F, Arcuri F, et al. Cellular kinetics and expression of bcl-2 and p53 in ductal carcinoma of the breast. Oncol Rep. May–Jun. 2000;7(3):473-8. Not eligible outcomes. [pmid: 10767354].
1726 Megha T, Ferrari F, Benvenuto A, et al. p53 mutation in breast cancer. Correlation with cell kinetics and cell of origin. J Clin Pathol. Jun. 2002;55(6):461-6. Not eligible outcomes. [pmid: 12037031].
1727 Mehl-Madrona L. Integrative tumor board: recurrent breast cancer or new primary? Mind-body-spirit medicine. Integr Cancer Ther. Sep. 2003;2(3):283-9. Case Reports. [pmid: 15035893].
1728 Meijnen P, Peterse JL, Antonini N, et al. Immunohistochemical categorisation of ductal carcinoma in situ of the breast. Br J Cancer. Jan. 15. 2008;98(1):137-42. Not eligible outcomes. [pmid: 18043578].
1729 Meijnen P, Peterse JL, Oldenburg HS, et al. Changing patterns in diagnosis and treatment of ductal carcinoma in situ of the breast. Eur J Surg Oncol. Oct. 2005;31(8):833-9. Not eligible outcomes. [pmid: 15923104].
1730 Meijnen P, Rutgers EJ. Meta-analysis of sentinel node biopsy in ductal carcinoma in situ of the breast (Br J Surg 2008; 95: 547-554). Br J Surg. Oct. 2008;95(10):1305. author reply Comment. [pmid: 18763257].
1731 Mellink WA, Holland R, Hendriks JH, et al. The contribution of routine follow-up mammography to an early detection of asynchronous contralateral breast cancer. Cancer. Apr. 1. 1991;67(7):1844-8. Not eligible outcomes. [pmid: 1848469].
1732 Melnikov AA, Scholtens DM, Wiley EL, et al. Array-based multiplex analysis of DNA methylation in breast cancer tissues. J Mol Diagn. Jan. 2008;10(1):93-101. Not eligible outcomes. [pmid: 18165279].
1733 Meltzer P, Leibovitz A, Dalton W, et al. Establishment of two new cell lines derived from human breast carcinomas with HER-2/neu amplification. Br J Cancer. May. 1991;63(5):727-35. Not eligible outcomes. [pmid: 1674877].
1734 Menes TS, Tartter PI, Mizrachi H, et al. Touch preparation or frozen section for intraoperative detection of sentinel lymph node metastases from breast cancer. Ann Surg Oncol. Dec. 2003;10(10):1166-70. Not eligible target population. [pmid: 14654472].
1735 Menon S, Porter GJ, Evans AJ, et al. The significance of lobular neoplasia on needle core biopsy of the breast. Virchows Arch. May. 2008;452(5):473-9. Not eligible target population. [pmid: 18389278].
1736 Mercado CL, Hamele-Bena D, Oken SM, et al. Papillary lesions of the breast at percutaneous core-needle biopsy. Radiology. Mar. 2006;238(3):801-8. Not eligible outcomes. [pmid: 16424237].
1737 Mercado CL, Hamele-Bena D, Singer C, et al. Papillary lesions of the breast: evaluation with stereotactic directional vacuum-assisted biopsy. Radiology. Dec. 2001;221(3):650-5. Not eligible outcomes. [pmid: 11719659].
1738 Mercer PM, Ebbs SR, Fraser SC, et al. Trial of aminoglutethimide vs hydrocortisone as second-line hormone treatment of advanced breast cancer. Eur J Surg Oncol. Jun. 1993;19(3):254-8. Not eligible target population. [pmid: 8314383].
1739 Merchant TE, Obertop H, de Graaf PW. Advantages of magnetic resonance imaging in breast surgery treatment planning. Breast Cancer Res Treat. 1993;25(3):257-64. Not eligible outcomes. [pmid: 8396465].
1740 Mertani HC, Garcia-Caballero T, Lambert A, et al. Cellular expression of growth hormone and prolactin receptors in human breast disorders. Int J Cancer. Apr. 17. 1998;79(2):202-11. Not eligible outcomes. [pmid: 9583737].
1741 Messina MJ, Wood CE. Soy isoflavones, estrogen therapy, and breast cancer risk: analysis and commentary. Nutrition Journal. 2008;7(1):17. Not eligible outcomes. [pmid: 18522734].
1742 Mesurolle B, Kethani K, El-Khoury M, et al. Intraductal papilloma in a reconstructed breast: mammographic and sonographic appearance with pathologic correlation. Breast. Oct. 2006;15(5):680-2. Case Reports. [pmid: 16448815].
1743 Meteoglu I, Dikicioglu E, Erkus M, et al. Breast carcinogenesis. Transition from hyperplasia to invasive lesions. Saudi Med J. Dec. 2005;26(12):1889-96. Not eligible outcomes. [pmid: 16380768].
1744 Meyer JE, Christian RL, Lester SC, et al. Evaluation of nonpalpable solid breast masses with stereotaxic large-needle core biopsy using a dedicated unit. AJR Am J Roentgenol. Jul. 1996;167(1):179-82. Not eligible outcomes. [pmid: 8659367].
1745 Meyer JE, Eberlein TJ, Stomper PC, et al. Biopsy of occult breast lesions. Analysis of 1261 abnormalities. JAMA. May. 2. 1990;263(17):2341-3. Not eligible outcomes. [pmid: 2157903].
1746 Meyer P, James VJ. Experimental confirmation of a distinctive diffraction pattern in hair from women with breast cancer. J Natl Cancer Inst. Jun. 6. 2001;93(11):873-5. Not eligible target population. [pmid: 11390537].
1747 Mezi S, Scopinaro F, Marzullo A, et al. 99m Tc MIBI prone scintimammography in breast Paget’s disease: a case report. Oncol Rep. Jan–Feb. 1999;6(1):45-8. Case Reports. [pmid: 9864399].
1748 Michael CW, Buschmann B. Can true papillary neoplasms of breast and their mimickers be accurately classified by cytology. Cancer. Apr. 25. 2002;96(2):92-100. Not eligible outcomes. [pmid: 11954026].
1749 Middleton LP, Amin M, Gwyn K, et al. Breast carcinoma in pregnant women: assessment of clinicopathologic and immunohistochemical features. Cancer. Sep. 1. 2003;98(5):1055-60. Not eligible outcomes. [pmid: 12942575].
1750 Miglioretti DL, Rutter CM, Geller BM, et al. Effect of breast augmentation on the accuracy of mammography and cancer characteristics. JAMA. Jan. 28. 2004;291(4):442-50. Not eligible outcomes. [pmid: 14747501].
1751 Miki Y, Clyne CD, Suzuki T, et al. Immunolocalization of liver receptor homologue-1 (LRH-1) in human breast carcinoma: possible regulator of insitu steroidogenesis. Cancer Lett. Nov. 28. 2006;244(1):24-33. Not eligible outcomes. [pmid: 16427184].
1752 Milchgrub S, Campuzano M, Casillas J, et al. Intraductal carcinoma of the pancreas. Cancer. Feb. 1. 1992;69(3):651-6. Case Reports. [pmid: 1309676].
1753 Millar EK, Tran K, Marr P, et al. p27KIP-1, cyclin A and cyclin D1 protein expression in ductal carcinoma in situ of the breast: p27KIP-1 correlates with hormone receptor status but not with local recurrence. Pathol Int. Apr. 2007;57(4):183-9. Not eligible outcomes. [pmid: 17316413].
1754 Milla-Santos A, Milla L, Portella J, et al. Anastrozole versus tamoxifen as first-line therapy in postmenopausal patients with hormone-dependent advanced breast cancer: a prospective, randomized, phase III study. Am J Clin Oncol. Jun. 2003;26(3):317-22. Not eligible target population. [pmid: 12796608].
1755 Miller AR, Brandao G, Prihoda TJ, et al. Positive margins following surgical resection of breast carcinoma: analysis of pathologic correlates. J Surg Oncol. Jun. 1. 2004;86(3):134-40. Not eligible outcomes. [pmid: 15170651].
1756 Miller DR, Cesario TC, Slater LM. Mondor’s disease associated with metastatic axillary nodes. Cancer. Aug. 15. 1985;56(4):903-4. Case Reports. [pmid: 2990659].
1757 Miller JW, Borowsky AD, Marple TC, et al. Folate, DNA methylation, and mouse models of breast tumorigenesis. Nutr Rev. Aug. 2008;66(Suppl 1):S59-64. Not eligible target population. [pmid: 18673493].
1758 Miller KL, Marks LB, Barrier RC Jr, et al. Increased sectioning of pathologic specimens with ductal carcinoma in situ of the breast: are there clinical consequences. Clin Breast Cancer. Aug. 2003;4(3):198-202. Not eligible outcomes. [pmid: 14499013].
1759 Miller RS, Adelman RW, Espinosa MH, et al. The early detection of nonpalpable breast carcinoma with needle localization. Experience with 500 patients in a community hospital. Am Surg. Mar. 1992;58(3):193-8. Not eligible outcomes. [pmid: 1313665].
1760 Miller WR, Stuart M, Sahmoud T, et al. Anastrozole (‘Arimidex’) blocks oestrogen synthesis both peripherally and within the breast in postmenopausal women with large operable breast cancer. Br J Cancer. Oct. 9. 2002;87(21):950-5. Not eligible target population. [pmid: 12434282].
1761 Millis RR, Pinder SE, Ryder K, et al. Grade of recurrent in situ and invasive carcinoma following treatment of pure ductal carcinoma in situ of the breast. Br J Cancer. Apr. 19. 2004;90(8):1538-42. Not eligible target population. [pmid: 15083182].
1762 Mills JM, Schultz DJ, Solin LJ. Preservation of cosmesis with low complication risk after conservative surgery and radiotherapy for ductal carcinoma in situ of the breast. Int J Radiat Oncol Biol Phys. Oct. 1. 1997;39(3):637-41. Not eligible level of evidence. [pmid: 9336143].
1763 Mills KM, Johnson DM, Middlebrooks M, et al. Possible drug-associated pancreatitis after paclitaxel-cremophor administration. Pharmacotherapy. Jan. 2000;20(1):95-7. Case Reports. [pmid: 10641981].
1764 Milsted R, Habeshaw T, Kaye S, et al. A randomised trial of tamoxifen versus tamoxifen with aminoglutethimide in post-menopausal women with advanced breast cancer. Cancer Chemother Pharmacol. 1985;14(3):272-3. Not eligible target population. [pmid: 3888433].
1765 Minami Y, Ohuchi N, Taeda Y, et al. Risk Factors for Benign Breast Disease according to Histopathological Type: Comparisons with Risk Factors for Breast. Japanese Journal of Cancer Research. 1998;89(2):116-23. Not eligible target population. [pmid: 9548437].
1766 Minor GI, Yashar CM, Spanos WJ Jr, et al. The relationship of radiation pneumonitis to treated lung volume in breast conservation therapy. Breast J. Jan–Feb. 2006;12(1):48-52. Not eligible target population. [pmid: 16409586].
1767 Mirer E, El Sayed F, Ammoury A, et al. Treatment of mammary and extramammary Paget’s skin disease with topical imiquimod. J Dermatolog Treat. 2006;17(3):167-71. Case Reports. [pmid: 16854759].
1768 Mirza M, Shaughnessy E, Hurley JK, et al. Osteopontin-c is a selective marker of breast cancer. International Journal of Cancer. Feb. 15. 2008;122(4):889-97. Not eligible outcomes.
1769 Mitchell EL, Woodhouse B, Birch JM, et al. The expression of aphidicolin-induced fragile sites in familial breast cancer patients. Cancer Genet Cytogenet. Jun. 1993;67(2):108-12. Not eligible outcomes. [pmid: 8392434].
1770 Mitchell G, Antoniou AC, Warren R, et al. Mammographic density and breast cancer risk in BRCA1 and BRCA2 mutation carriers. 2006. Not eligible outcomes.
1771 Mitchell ML, Napoletano J, Penman EJ. The MRI appearance of Paget’s disease of the nipple: images from a single case. Del Med J. Mar. 2006;78(3):105-6. Case Reports. [pmid: 16597091].
1772 Mitchell RE. Mammary and extramammary Paget’s disease. Australas J Dermatol. Aug. 1974;15(2):51-63. Not eligible target population. [pmid: 4374923].
1773 Mitchell S, Lachica R, Randall MB, et al. Paget’s disease of the breast areola mimicking cutaneous melanoma. Breast J. May–Jun. 2006;12(3):233-6. Case Reports. [pmid: 16684321].
1774 Mitnick JS, Gianutsos R, Pollack AH, et al. Tubular carcinoma of the breast: sensitivity of diagnostic techniques and correlation with histopathology. AJR Am J Roentgenol. Feb. 1999;172(2):319-23. Not eligible outcomes. [pmid: 9930775].
1775 Mitnick JS, Vazquez MF, Feiner HD, et al. Mammographically detected breast lesions: clinical importance of cytologic atypia in stereotaxic fine-needle aspiration biopsy samples. Radiology. Feb. 1996;198(2):319-22. Not eligible outcomes. [pmid: 8596824].
1776 Mitnick JS, Vazquez MF, Roses DF, et al. Stereotactic localization for fine needle aspiration biopsy in patients with augmentation prostheses. Ann Plast Surg. Jul. 1992;29(1):31-5. Not eligible outcomes. [pmid: 1323231].
1777 Miyazaki M, Tamaki Y, Sakita I, et al. Detection of microsatellite alterations in nipple discharge accompanied by breast cancer. Breast Cancer Res Treat. Mar. 2000;60(1):35-41. Not eligible outcomes. [pmid: 10845807].
1778 Miyoshi Y, Iwao K, Ikeda N, et al. Genetic polymorphism in CYP17 and breast cancer risk in Japanese women. European Journal of Cancer. 2000;36(18):2375-9. Not eligible outcomes. [pmid: 11094312].
1779 Mizogami M, Sakurai S, Kikuchi M, et al. Application of the AMeX method to the evaluation of HER-2 status in breast carcinomas: comparison with the results of HercepTest. Pathol Int. Jan. 2003;53(1):27-9. Not eligible outcomes. [pmid: 12558866].
1780 Mizukami Y, Nonomura A, Noguchi M, et al. Immunohistochemical study of oncogene product ras p21, c-myc and growth factor EGF in breast carcinomas. Anticancer Res. Jul–Aug. 1991;11(4):1485-94. Not eligible outcomes. [pmid: 1660689].
1781 Mo YH, Wang J, Kuo WH, et al. Intraductal papillary carcinoma of bilateral breasts: a case report. Clin Imaging. Nov–Dec. 2003;27(6):394-7. Case Reports. [pmid: 14585566].
1782 Moate PJ, Dougherty L, Schnall MD, et al. A modified logistic model to describe gadolinium kinetics in breast tumors. Magn Reson Imaging. May. 2004;22(4):467-73. Not eligible outcomes. [pmid: 15120165].
1783 Moe RE, Moe KS, Porter P, et al. Expression of Her-2/neu oncogene protein product and epidermal growth factor receptors in surgical specimens of human breast cancers. Am J Surg. May. 1991;161(5):580-3. Not eligible outcomes. [pmid: 1674411].
1784 Moinfar F, Man YG, Arnould L, et al. Concurrent and independent genetic alterations in the stromal and epithelial cells of mammary carcinoma: implications for tumorigenesis. Cancer Res. May. 1. 2000;60(9):2562-6. Not eligible outcomes. [pmid: 10811140].
1785 Moinfar F, Man YG, Bratthauer GL, et al. Genetic abnormalities in mammary ductal intraepithelial neoplasia-flat type (“clinging ductal carcinoma in situ”): a simulator of normal mammary epithelium. Cancer. May. 1. 2000;88(9):2072-81. Not eligible target population. [pmid: 10813719].
1786 Moinfar F, Okcu M, Tsybrovskyy O, et al. Androgen receptors frequently are expressed in breast carcinomas: potential relevance to new therapeutic strategies. Cancer. Aug. 15. 2003;98(4):703-11. Not eligible outcomes. [pmid: 12910513].
1787 Mokbel K, Choy C, Leris C, et al. Predictors of positive margins after local excision of ductal carcinoma in situ. Am J Surg. Feb. 2001;181(2):91-5. Not eligible outcomes. [pmid: 11425066].
1788 Moncrief RM, Nayar R, Diaz LK, et al. A comparison of ductoscopy-guided and conventional surgical excision in women with spontaneous nipple discharge. Ann Surg. Apr. 2005;241(4):575-81. Not eligible target population. [pmid: 15798458].
1789 Montgomery LL, Tran KN, Heelan MC, et al. Issues of regret in women with contralateral prophylactic mastectomies. Ann Surg Oncol. Sep. 1999;6(6):546-52. Not eligible outcomes. [pmid: 10493622].
1790 Monti S, Galimberti V, Trifiro G, et al. Occult breast lesion localization plus sentinel node biopsy (SNOLL): experience with 959 patients at the European Institute of Oncology. Ann Surg Oncol. Oct. 2007;14(10):2928-31. Not eligible target population. [pmid: 17674108].
1791 Monticciolo DL. Histologic grading at breast core needle biopsy: comparison with results from the excised breast specimen. Breast J. Jan–Feb. 2005;11(1):9-14. Not eligible outcomes. [pmid: 15647072].
1792 Moon WK, Noh DY, Im JG. Multifocal, multicentric, and contralateral breast cancers: bilateral whole-breast US in the preoperative evaluation of patients. Radiology. Aug. 2002;224(2):569-76. Not eligible outcomes. [pmid: 12147858].
1793 Morakkabati-Spitz N, Leutner C, Schild H, et al. Diagnostic usefulness of segmental and linear enhancement in dynamic breast MRI. Eur Radiol. Sep. 2005;15(9):2010-7. Not eligible outcomes. [pmid: 15841382].
1794 Moran MS, Yang Q, Harris LN, et al. Long-term outcomes and clinicopathologic differences of African-American versus white patients treated with breast conservation therapy for early-stage breast cancer. Cancer. Nov. 1. 2008;113(9):2565-74. Not eligible target population. [pmid: 18816610].
1795 Morandi L, Pession A, Marucci GL, et al. Intraepidermal cells of Paget’s carcinoma of the breast can be genetically different from those of the underlying carcinoma. Hum Pathol. Dec. 2003;34(12):1321-30. Not eligible target population. [pmid: 14691919].
1796 Moreno A, Figueras A, Lloveras B, et al. Apoptosis in ductal carcinoma in situ of the breast. Breast J. Jul–Aug. 2001;7(4):245-8. Not eligible outcomes. [pmid: 11678802].
1797 Moreno A, Lloveras B, Figueras A, et al. Ductal carcinoma in situ of the breast: correlation between histologic classifications and biologic markers. Mod Pathol. Nov. 1997;10(11):1088-92. Not eligible outcomes. [pmid: 9388058].
1798 Morimoto T, Okazaki K, Komaki K, et al. Cancerous residue in breast-conserving surgery. J Surg Oncol. Feb. 1993;52(2):71-6. Not eligible target population. [pmid: 8385722].
1799 Moritani S, Ichihara S, Kushima R, et al. Myoepithelial cells in solid variant of intraductal papillary carcinoma of the breast: a potential diagnostic pitfall and a proposal of an immunohistochemical panel in the differential diagnosis with intraductal papilloma with usual ductal hyperplasia. Virchows Arch. May. 2007;450(5):539-47. Not eligible target population. [pmid: 17377808].
1800 Moriya T, Silverberg SG. Intraductal carcinoma (ductal carcinoma in situ) of the breast. A comparison of pure noninvasive tumors with those including different proportions of infiltrating carcinoma. Cancer. Dec. 11. 1994;74(1):2972-8. Not eligible outcomes. [pmid: 7954261].
1801 Morohoshi T, Kunimura T, Kanda M, et al. Multiple carcinomata associated with anomalous arrangement of the biliary and pancreatic duct system. A report of two cases with a literature survey. Acta Pathol Jpn. Oct. 1990;40(10):755-63. Case Reports. [pmid: 1963257].
1802 Morris EA, Liberman L, Ballon DJ, et al. MRI of occult breast carcinoma in a high-risk population. AJR Am J Roentgenol. Sep. 2003;181(3):619-26. Not eligible level of evidence. [pmid: 12933450].
1803 Morris EA, Liberman L, Dershaw DD, et al. Preoperative MR imaging-guided needle localization of breast lesions. AJR Am J Roentgenol. May. 2002;178(5):1211-20. Not eligible exposure. [pmid: 11959734].
1804 Morris EA, Liberman L, Trevisan SG, et al. Histologic heterogeneity of masses at percutaneous breast biopsy. Breast J. Jul–Aug. 2002;8(4):187-91. Not eligible outcomes. [pmid: 12100109].
1805 Morris EA, Schwartz LH, Drotman MB, et al. Evaluation of pectoralis major muscle in patients with posterior breast tumors on breast MR images: early experience. Radiology. Jan. 2000;214(1):67-72. Not eligible outcomes. [pmid: 10644103].
1806 Morris J. Regional variation in the surgical treatment of early breast cancer. Br J Surg. Dec. 1992;79(12):1312-3. Not eligible outcomes. [pmid: 1336700].
1807 Morrogh M, Morris EA, Liberman L, et al. MRI identifies otherwise occult disease in select patients with Paget disease of the nipple. J Am Coll Surg. Feb. 2008;206(2):316-21. Not eligible level of evidence. [pmid: 18222386].
1808 Morrow M. A 47-year-old woman with ductal carcinoma in situ. JAMA. Jan. 3. 1996;275(1):61-6. Case Reports. [pmid: 8531289].
1809 Morrow M. Residual disease in DCIS: an excision too far. Cancer J. Jan–Feb. 2003;9(1):31-2. Comment. [pmid: 12602765].
1810 Morrow M. Axillary surgery in DCIS: is less more. Ann Surg Oncol. Oct. 2008;15(10):2641-2. Comment. [pmid: 18679753].
1811 Morrow M, Mujahid M, Lantz PM, et al. Correlates of breast reconstruction: results from a population-based study. Cancer. Dec. 1. 2005;104(11):2340-6. Not eligible outcomes. [pmid: 16216000].
1812 Morrow M, Schmidt R, Cregger B, et al. Preoperative evaluation of abnormal mammographic findings to avoid unnecessary breast biopsies. Arch Surg. Oct. 1994;129(10):1091-6. Not eligible exposure. [pmid: 7944941].
1813 Morrow M, Schmidt R, Hassett C. Patient selection for breast conservation therapy with magnification mammography. Surgery. Oct. 1995;118(4):621-6. Not eligible outcomes. [pmid: 7570314].
1814 Morrow M, Scott SK, Menck HR, et al. Factors influencing the use of breast reconstruction postmastectomy: a National Cancer Database study. J Am Coll Surg. Jan. 2001;192(1):1-8. Not eligible outcomes. [pmid: 11192909].
1815 Morton AL, Butler SA, Khan A, et al. Temporal bone metastases--pathophysiology and imaging. Otolaryngol Head Neck Surg. Dec. 1987;97(6):583-7. Case Reports. [pmid: 2829099].
1816 Moskovic E, Sinnett HD, Parsons CA. The accuracy of mammographic diagnosis in surgically occult breast lesions. Clin Radiol. May. 1990;41(5):344-6. Not eligible outcomes. [pmid: 2354604].
1817 Moss WT. Conservative surgery and radiation for intraductal breast carcinoma. JAMA. Jul. 8. 1992;268(2):266. Comment. [pmid: 1318979].
1818 Mourad WA. Aneuploidy in sclerosing adenosis may predict an increased risk of malignancy. A study using the AgNOR silver stain. Pathology. Aug. 1997;29(3):255-9. Not eligible outcomes. [pmid: 9271010].
1819 Mourad WA, Erkman-Balis B, Livingston S, et al. Argyrophilic nucleolar organizer regions in breast carcinoma. Correlation with DNA flow cytometry, histopathology, and lymph node status. Cancer. Apr. 1. 1992;69(7):1739-44. Not eligible outcomes. [pmid: 1312892].
1820 Mouridsen H, Chaudri-Ross HA. Efficacy of first-line letrozole versus tamoxifen as a function of age in postmenopausal women with advanced breast cancer. Oncologist. 2004;9(5):497-506. Not eligible target population. [pmid: 15477634].
1821 Mouridsen H, Gershanovich M, Sun Y, et al. Superior efficacy of letrozole versus tamoxifen as first-line therapy for postmenopausal women with advanced breast cancer: results of a phase III study of the International Letrozole Breast Cancer Group. J Clin Oncol. May. 15. 2001;19(10):2596-606. Not eligible target population. [pmid: 11352951].
1822 Mouridsen H, Keshaviah A, Coates AS, et al. Cardiovascular adverse events during adjuvant endocrine therapy for early breast cancer using letrozole or tamoxifen: safety analysis of BIG 1-98 trial. J Clin Oncol. Dec. 20. 2007;25(36):5715-22. Not eligible target population. [pmid: 17998546].
1823 Mouridsen H, Sun Y, Gershanovich M, et al. Superiority of letrozole to tamoxifen in the first-line treatment of advanced breast cancer: evidence from metastatic subgroups and a test of functional ability. Oncologist. 2004;9(5):489-96. Not eligible target population. [pmid: 15477633].
1824 Mouridsen HT. Letrozole in advanced breast cancer: the PO25 trial. Breast Cancer Res Treat. 2007;105(Suppl 1):19-29. Not eligible target population. [pmid: 17333340].
1825 Moy B, Tu D, Pater JL, et al. Clinical outcomes of ethnic minority women in MA.17: a trial of letrozole after 5 years of tamoxifen in postmenopausal women with early stage breast cancer. Ann Oncol. Nov. 2006;17(11):1637-43. Not eligible target population. [pmid: 16936184].
1826 Mrhalova M, Kodet R. Paget’s disease of the nipple: a copy number of the genes ERBB2 and CCND1 versus expression of the proteins ERBB-2 and cyclin D1. Neoplasma. 2003;50(6):396-402. Not eligible target population. [pmid: 14689059].
1827 Mucci-LoRusso P, Polin L, Biernat LA, et al. Activity of datelliptium acetate (NSC 311152; SR 95156A) against solid tumors of mice. Invest New Drugs. Aug. 1990;8(3):253-61. Not eligible target population. [pmid: 2177044].
1828 Mueller C, Riese U, Kosmehl H, et al. Telomerase activity in microdissected human breast cancer tissues: association with p53, p21 and outcome. Int J Oncol. Feb. 2002;20(2):385-90. Not eligible outcomes. [pmid: 11788906].
1829 Mueller JH, Lukas GM. Clinicopathologic correlations of eighty nonpalpable breast lesions. IMJ Ill Med J. May. 1988;173(5):321-4. Not eligible outcomes. [pmid: 2899067].
1830 Mugler KC, Marshall C, Hardesty L, et al. Intracystic papillary carcinoma of the breast: differential diagnosis and management. Oncology (Williston Park). Jun. 2007;21(7):871-6. Case Reports. [pmid: 17722745].
1831 Mula C. Breast cancer: a nursing care study. Nursing (Lond). Aug. 23–Sep 12. 1990;4(17):23-7. Case Reports. [pmid: 2172877].
1832 Mulay IL, Roy R, Knox BE, et al. Trace-metal analysis of cancerous and noncancerous human tissues. J Natl Cancer Inst. Jul. 1971;47(1):1-13. Not eligible outcomes. [pmid: 4328191].
1833 Mumtaz H, Hall-Craggs MA, Davidson T, et al. Staging of symptomatic primary breast cancer with MR imaging. AJR Am J Roentgenol. Aug. 1997;169(2):417-24. Not eligible level of evidence. [pmid: 9242745].
1834 Munson-Bernardi BD, DePersia LA. Amyloidosis of the breast coexisting with ductal carcinoma in situ. AJR Am J Roentgenol. Jan. 2006;186(1):54-5. Case Reports. [pmid: 16357378].
1835 Murad TM, Contesso G, Mouriesse H. Nipple discharge from the breast. Ann Surg. Mar. 1982;195(3):259-64. Not eligible target population. [pmid: 6277258].
1836 Murakami Y, Yokoyama T, Kodama T, et al. Mucin-producing pancreatic tumors: a study of nuclear DNA content by flow cytometry. Surg Today. 1993;23(6):491-5. Not eligible target population. [pmid: 8395265].
1837 Murayama Y. Growth-inhibitory effects of epidermal growth factor on human breast cancer and carcinoma of the esophagus transplanted into nude mice. Ann Surg. Mar. 1990;211(3):263-8. Not eligible target population. [pmid: 2155590].
1838 Murray PA, Barrett-Lee P, Travers M, et al. The prognostic significance of transforming growth factors in human breast cancer. Br J Cancer. Jun. 1993;67(6):1408-12. Not eligible target population. [pmid: 8390290].
1839 Muss HB, Tu D, Ingle JN, et al. Efficacy, toxicity, and quality of life in older women with early-stage breast cancer treated with letrozole or placebo after 5 years of tamoxifen: NCIC CTG intergroup trial MA.17. J Clin Oncol. Apr. 20. 2008;26(12):1956-64. Not eligible target population. [pmid: 18332474].
1840 Mussurakis S, Buckley DL, Bowsley SJ, et al. Dynamic contrast-enhanced magnetic resonance imaging of the breast combined with pharmacokinetic analysis of gadolinium-DTPA uptake in the diagnosis of local recurrence of early stage breast carcinoma. Invest Radiol. Nov. 1995;30(11):650-62. Not eligible outcomes. [pmid: 8557506].
1841 Mustac E, Zamolo G, Petkovic M, et al. Breast infiltrating ductal carcinoma: analysis of hormone, HER-2 receptors and Ki-67 proliferation marker. Coll Antropol. Sep. 2008;32(3):741-6. Not eligible target population. [pmid: 18982746].
1842 Muttarak M, Chaiwun B, Trakultivakorn H. Case quiz. Intracystic papillary carcinoma of the breast. Australas Radiol. Mar. 2002;46(1):129-31. Case Reports. [pmid: 11966605].
1843 Myers JL, Mazur MT, Urist MM, et al. Florid papillomatosis of the nipple: immunohistochemical and flow cytometric analysis of two cases. Mod Pathol. May. 1990;3(3):288-93. Case Reports. [pmid: 2163532].
1844 Nabholtz JM, Buzdar A, Pollak M, et al. Anastrozole is superior to tamoxifen as first-line therapy for advanced breast cancer in postmenopausal women: results of a North American multicenter randomized trial. Arimidex Study Group. J Clin Oncol. Nov. 15. 2000;18(22):3758-67. Not eligible target population. [pmid: 11078488].
1845 Nabili V, Tan JW, Bhuta S, et al. Salivary duct carcinoma: a clinical and histologic review with implications for trastuzumab therapy. Head Neck. Oct. 2007;29(10):907-12. not eligible target population. [pmid: 17563907].
1846 Nadeem R, Chagla LS, Harris O, et al. Tumour localisation with a metal coil before the administration of neo-adjuvant chemotherapy. Breast. Oct. 2005;14(5):403-7. Not eligible target population. [pmid: 16216744].
1847 Nadkarni MS, Gupta PB, Parmar VV, et al. Breast conservation surgery without pre-operative mammography--a definite feasibility. Breast. Oct. 2006;15(5):595-600. Not eligible outcomes. [pmid: 16517163].
1848 Nagashima T, Hashimoto H, Oshida K, et al. Ultrasound Demonstration of Mammographically Detected Microcalcifications in Patients with Ductal Carcinoma in situ of the Breast. Breast Cancer. 2005;12(3):216-20. Not eligible outcomes. [pmid: 16110292].
1849 Nagashima T, Suzuki M, Yagata H, et al. Cytomorphometric differentiation of intraductal proliferative breast lesions. Breast Cancer. Jan. 2000;7(1):43-7. Not eligible outcomes. [pmid: 11029770].
1850 Nagi CS, O’Donnell JE, Tismenetsky M, et al. Lobular neoplasia on core needle biopsy does not require excision. Cancer. May. 15. 2008;112(10):2152-8. Not eligible target population. [pmid: 18348299].
1851 Nahleh Z, Namakydoust A, Bakkar R, et al. Trastuzumab not for ductal carcinoma in situ. Anticancer Drugs. Nov. 2007;18(10):1231-5. Case Reports. [pmid: 17893526].
1852 Naidu R, Wahab NA, Yadav M, et al. Detection of amplified int-2/FGF-3 gene in primary breast carcinomas using differential polymerase chain reaction. Int J Mol Med. Aug. 2001;8(2):193-8. Not eligible outcomes. [pmid: 11445874].
1853 Naidu R, Wahab NA, Yadav MM, et al. Expression and amplification of cyclin D1 in primary breast carcinomas: relationship with histopathological types and clinico-pathological parameters. Oncol Rep. Mar–Apr. 2002;9(2):409-16. Not eligible outcomes. [pmid: 11836618].
1854 Naidu R, Yadav M, Nair S, et al. Expression of c-erbB3 protein in primary breast carcinomas. Br J Cancer. Nov. 1998;78(10):1385-90. Not eligible outcomes. [pmid: 9823984].
1855 Nakahara H, Namba K, Fukami A, et al. Three-dimensional MR imaging of mammographically detected suspicious microcalcifications. Breast Cancer. 2001;8(2):116-24. Not eligible outcomes. [pmid: 11342984].
1856 Nakahara H, Namba K, Wakamatsu H, et al. Extension of breast cancer: comparison of CT and MRI. Radiat Med. Jan–Feb. 2002;20(1):17-23. Not eligible outcomes. [pmid: 12002599].
1857 Nakahara H, Namba K, Watanabe R, et al. A comparison of MR imaging, galactography and ultrasonography in patients with nipple discharge. Breast Cancer. 2003;10(4):320-9. Not eligible outcomes. [pmid: 14634510].
1858 Nakajima E, Iwata H, Iwase T, et al. Four cases of chylous fistula after breast cancer resection. Breast Cancer Res Treat. Jan. 2004;83(1):11-4. Not eligible target population. [pmid: 14997050].
1859 Nakamori S, Ishikawa O, Ohhigashi H, et al. Expression of nucleoside diphosphate kinase/nm23 gene product in human pancreatic cancer: an association with lymph node metastasis and tumor invasion. Clin Exp Metastasis. Mar. 1993;11(2):151-8. Not eligible target population. [pmid: 8383029].
1860 Nakamura Y, Yasuoka H, Tsujimoto M, et al. Flt-4-positive vessel density correlates with vascular endothelial growth factor-d expression, nodal status, and prognosis in breast cancer. Clin Cancer Res. Nov. 1. 2003;9(14):5313-7. Not eligible outcomes. [pmid: 14614015].
1861 Nakano S, Sakamoto H, Ohtsuka M, et al. Evaluation and indications of ultrasound-guided vacuum-assisted core needle breast biopsy. Breast Cancer. 2007;14(3):292-6. Not eligible outcomes. [pmid: 17690507].
1862 Nakhlis F, Lazarus L, Hou N, et al. Tamoxifen use in patients with ductal carcinoma in situ and T1a/b N0 invasive carcinoma. J Am Coll Surg. Nov. 2005;201(5):688-94. Not eligible outcomes. [pmid: 16256910].
1863 Nakopoulou L, Katsarou S, Giannopoulou I, et al. Correlation of tissue inhibitor of metalloproteinase-2 with proliferative activity and patients’ survival in breast cancer. Mod Pathol. Jan. 2002;15(1):26-34. Not eligible outcomes. [pmid: 11796838].
1864 Nakopoulou L, Lekkas N, Lazaris AC, et al. An immunohistochemical analysis of angiogenesis in invasive breast cancer with correlations to clinicopathologic predictors. Anticancer Res. Sep–Oct. 1999;19(5C):4547-53. Not eligible outcomes. [pmid: 10650809].
1865 Nalwoga H, Arnes JB, Wabinga H, et al. Expression of EGFR and c-kit is associated with the basal-like phenotype in breast carcinomas of African women. APMIS. Jun. 2008;116(6):515-25. Not eligible outcomes. [pmid: 18754326].
1866 Namba R, Young LJ, Maglione JE, et al. Selective estrogen receptor modulators inhibit growth and progression of premalignant lesions in a mouse model of ductal carcinoma in situ. Breast Cancer Res. 2005;7(6):R881-9. Not eligible target population. [pmid: 16280035].
1867 Nambisan M, Elwood E, Mammolito D. Locally recurrent angiosarcoma after excision in a patient treated with breast-conserving therapy. Am Surg. Dec. 2008;74(12):1227-8. Case Reports. [pmid: 19097548].
1868 Napoles-Springer AM, Livaudais JC, Bloom J, et al. Information exchange and decision making in the treatment of Latina and white women with ductal carcinoma in situ. J Psychosoc Oncol. 2007;25(4):19-36. Not eligible outcomes. [pmid: 18032263].
1869 Narita T, Funahashi H, Satoh Y, et al. Proliferating cell nuclear antigen immunostaining in breast cancer and its relation to prognosis. Jpn J Clin Oncol. Feb. 1993;23(1):20-5. Not eligible outcomes. [pmid: 8096256].
1870 Nasir N, Rainsbury RM. The timing of surgery affects the detection of residual disease after wide local excision of breast carcinoma. Eur J Surg Oncol. Nov. 2003;29(9):718-20. Not eligible outcomes. [pmid: 14602489].
1871 Nathanson SD, Burke M, Slater R, et al. Preoperative identification of the sentinel lymph node in breast cancer. Ann Surg Oncol. Nov. 2007;14(11):3102-10. Not eligible target population. [pmid: 17661149].
1872 Nava MB, Cortinovis U, Ottolenghi J, et al. Skin-reducing mastectomy. Plast Reconstr Surg. Sep. 2006;118(3):603-10. discussion 11-3. Not eligible target population. [pmid: 16932166].
1873 Nayar R, De Frias DV, Bourtsos EP, et al. Cytologic differential diagnosis of papillary pattern in breast aspirates: correlation with histology. Ann Diagn Pathol. Feb. 2001;5(1):34-42. Not eligible outcomes. [pmid: 11172205].
1874 Neave L, Harvey V, Benjamin C, et al. The Auckland Breast Cancer Register: a special project of the Auckland Breast Cancer Study Group. N Z Med J. Oct. 24. 2003;116(1184):U648. Not eligible target population. [pmid: 14583806].
1875 Neelakantan P, McLean SR, Kenny S, et al. Breast cancer metastasizing to the tongue. Can J Surg. Jun. 2008;51(3):E63-4. Case Reports. [pmid: 18682793].
1876 Nemoto T, Patel JK, Rosner D, et al. Factors affecting recurrence in lumpectomy without irradiation for breast cancer. Cancer. Apr. 15. 1991;67(8):2079-82. Not eligible target population. [pmid: 1848474].
1877 Nerlich AG, Wiest I, Wagner E, et al. Gene expression and protein deposition of major basement membrane components and TGF-beta 1 in human breast cancer. Anticancer Res. Nov–Dec. 1997;17(6D):4443-9. Not eligible outcomes. [pmid: 9494547].
1878 Neubauer H, Li M, Kuehne-Heid R, et al. High grade and non-high grade ductal carcinoma in situ on dynamic MR mammography: characteristic findings for signal increase and morphological pattern of enhancement. Br J Radiol. Jan. 2003;76(901):3-12. Not eligible level of evidence. [pmid: 12595319].
1879 Neuschatz AC, DiPetrillo T, Steinhoff M, et al. The value of breast lumpectomy margin assessment as a predictor of residual tumor burden in ductal carcinoma in situ of the breast. Cancer. Apr. 1. 2002;94(7):1917-24. Not eligible outcomes. [pmid: 11932892].
1880 Newcomer LM, Newcomb PA, Potter JD, et al. Postmenopausal hormone therapy and risk of breast cancer by histologic type (United States). Cancer Causes Control. Apr. 2003;14(3):225-33. Not eligible outcomes. [pmid: 12814201].
1881 Newman LA, Sahin AA, Cunningham JE, et al. A case-control study of unilateral and bilateral breast carcinoma patients. Cancer. May. 15. 2001;91(10):1845-53. Not eligible target population. [pmid: 11346865].
1882 Newman PD, Mason BH, Holdaway IM, et al. Incidence and clinical features of breast cancer in the Auckland region. N Z Med J. Apr. 8. 1992;105(931):117-20. Not eligible target population. [pmid: 1313956].
1883 Ng EH, Chiang G, Sng I, et al. Difficulty of obtaining wide tumour to deep fascial margins in Asian women with breast cancers: implications on treatment and prognosis. Ann Acad Med Singapore. Mar. 1996;25(2):241-4. Not eligible outcomes. [pmid: 8799014].
1884 Ng EH, Ng FC, Tan PH, et al. Results of intermediate measures from a population-based, randomized trial of mammographic screening prevalence and detection of breast carcinoma among Asian women: the Singapore Breast Screening Project. Cancer. Apr. 15. 1998;82(8):1521-8. Not eligible outcomes. [pmid: 9554530].
1885 Nicholson S, Richard J, Sainsbury C, et al. Epidermal growth factor receptor (EGFr); results of a 6 year follow-up study in operable breast cancer with emphasis on the node negative subgroup. Br J Cancer. Jan. 1991;63(1):146-50. Not eligible target population. [pmid: 1846551].
1886 Nicolas MM, Nayar R, Yeldandi A, et al. Pulmonary metastasis of a postradiation breast epithelioid angiosarcoma mimicking adenocarcinoma. A case report. Acta Cytol. Nov–Dec. 2006;50(6):672-6. Case Reports. [pmid: 17152281].
1887 Nicolas MM, Wu Y, Middleton LP, et al. Loss of myoepithelium is variable in solid papillary carcinoma of the breast. Histopathology. Nov. 2007;51(5):657-65. Not eligible target population. [pmid: 17927587].
1888 Nicoletti G, Scevola S, Ruggiero R, et al. Gigantic Paget disease of the breast. Breast. Oct. 2004;13(5):425-7. Case Reports. [pmid: 15454200].
1889 Nielsen B. Haemangiomas of the breast. Pathol Res Pract. Mar. 2. 1983:176-4. 253. 7. Case Reports.
1890 Nielsen M, Jensen J, Andersen J. Precancerous and cancerous breast lesions during lifetime and at autopsy. A study of 83 women. Cancer. Aug. 15. 1984;54(4):612-5. Not eligible outcomes. [pmid: 6744199].
1891 Nielsen M, Thomsen JL, Primdahl S, et al. Breast cancer and atypia among young and middle-aged women: a study of 110 medicolegal autopsies. Br J Cancer. Dec. 1987;56(6):814-9. Not eligible target population. [pmid: 2829956].
1892 Nieweg OE, Kim EE, Wong WH, et al. Positron emission tomography with fluorine-18-deoxyglucose in the detection and staging of breast cancer. Cancer. Jun. 15. 1993;71(12):3920-5. Not eligible outcomes. [pmid: 8389655].
1893 Niewiadomska H, Mirowski M, Stempien M, et al. Immunohistochemical analysis of expression of a 65 kDa oncofetal protein (p65), epidermal growth factor receptor (EGFR), oncogene c-erb references.r2 and tumor suppressor gene p53 protein products in breast cancer patients. Neoplasma. 2000;47(1):8-14. Not eligible outcomes. [pmid: 10870681].
1894 Nishida M, Johno N, Murakami T, et al. Usefulness of galactography for minimal noninvasive ductal carcinoma of the breast. Nippon Geka Hokan. Mar. 1. 1989;58(2):250-6. Case Reports. [pmid: 2552951].
1895 Nishidate T, Katagiri T, Lin ML, et al. Genome-wide gene-expression profiles of breast-cancer cells purified with laser microbeam microdissection: identification of genes associated with progression and metastasis. Int J Oncol. Oct. 2004;25(4):797-819. Not eligible outcomes. [pmid: 15375528].
1896 Nishihara K, Fukuda T, Tsuneyoshi M, et al. Intraductal papillary neoplasm of the pancreas. Cancer. Aug. 1. 1993;72(3):689-96. Case Reports. [pmid: 8392902].
1897 Nishiki M, Amano K, Yamane M, et al. Microscopic carcinoma of the breast--report of a case. Jpn J Surg. May. 1984;14(3):235-8. Case Reports. [pmid: 6087000].
1898 Nishino M, Hayakawa K, Yamamoto A, et al. Multiple enhancing lesions detected on dynamic helical computed tomography-mammography. J Comput Assist Tomogr. Sep–Oct. 2003;27(5):771-8. Not eligible outcomes. [pmid: 14501369].
1899 Nobukawa B, Fujii H, Hirai S, et al. Breast carcinoma diverging to aberrant melanocytic differentiation: a case report with histopathologic and loss of heterozygosity analyses. Am J Surg Pathol. Oct. 1999;23(10):1280-7. Case Reports. [pmid: 10524531].
1900 Noguchi M, Earashi M, Fujii H, et al. Radiofrequency ablation of small breast cancer followed by surgical resection. J Surg Oncol. Feb. 1. 2006;93(2):120-8. Not eligible exposure. [pmid: 16425291].
1901 Noguchi M, Minami M, Earashi M, et al. Intraoperative histologic assessment of surgical margins and lymph node metastasis in breast-conserving surgery. J Surg Oncol. Nov. 1995;60(3):185-90. Not eligible outcomes. [pmid: 7475069].
1902 Noguchi M, Ohta N, Koyasaki N, et al. Reappraisal of internal mammary node metastases as a prognostic factor in patients with breast cancer. Cancer. Nov. 1. 1991;68(9):1918-25. Not eligible target population. [pmid: 1655229].
1903 Noguchi M, Taniya T, Ohta N, et al. Lymph node metastases versus DNA ploidy as prognostic factors for invasive ductal carcinoma of the breast. Breast Cancer Res Treat. Sep. 1991;19(1):23-31. Not eligible target population. [pmid: 1661623].
1904 Noguchi S, Koyama H, Kasugai T, et al. The possible prognostic significance of p53 immunostaining status of the primary tumor in patients developing local recurrence after breast-conserving surgery. Oncology. Sep–Oct. 1998;55(5):450-5. Not eligible level of evidence. [pmid: 9732224].
1905 Noguchi S, Motomura K, Inaji H, et al. Up-regulation of estrogen receptor by tamoxifen in human breast cancer. Cancer. Feb. 15. 1993;71(4):1266-72. Not eligible outcomes. [pmid: 8382104].
1906 Noguchi S, Motomura K, Inaji H, et al. Clonal analysis of predominantly intraductal carcinoma and precancerous lesions of the breast by means of polymerase chain reaction. Cancer Res. Apr. 1. 1994;54(7):1849-53. Not eligible outcomes. [pmid: 7907946].
1907 Nomura M, Inoue Y, Fujita S, et al. A case of noninvasive ductal carcinoma arising in malignant phyllodes tumor. Breast Cancer. 2006;13(1):89-94. Case Reports. [pmid: 16518067].
1908 Norton KS, McClusky D, Sen S, et al. TLK1B is elevated with eIF4E overexpression in breast cancer. J Surg Res. Jan. 2004;116(1):98-103. Not eligible target population. [pmid: 14732354].
1909 Nose T, Komoike Y, Yoshida K, et al. A pilot study of wider use of accelerated partial breast irradiation: intraoperative margin-directed re-excision combined with sole high-dose-rate interstitial brachytherapy. Breast Cancer. 2006;13(3):289-99. Not eligible target population. [pmid: 16929124].
1910 Ntziachristos V, Yodh AG, Schnall MD, et al. MRI-guided diffuse optical spectroscopy of malignant and benign breast lesions. Neoplasia. Jul–Aug. 2002;4(4):347-54. Not eligible outcomes. [pmid: 12082551].
1911 Nuyten DS, Kreike B, Hart AA, et al. Predicting a local recurrence after breast-conserving therapy by gene expression profiling. Breast Cancer Res. 2006;8(5):R62. Not eligible target population. [pmid: 17069664].
1912 Nyante SJ, Devries S, Chen YY, et al. Array-based comparative genomic hybridization of ductal carcinoma in situ and synchronous invasive lobular cancer. Hum Pathol. Jun. 2004;35(6):759-63. Case Reports. [pmid: 15188144].
1913 Nyante SJ, Gammon MD, Malone KE, et al. The association between oral contraceptive use and lobular and ductal breast cancer in young women. Int J Cancer. Feb. 15. 2008;122(4):936-41. Not eligible outcomes. [pmid: 17957781].
1914 Obara T, Maguchi H, Saitoh Y, et al. Mucin-producing tumor of the pancreas: natural history and serial pancreatogram changes. Am J Gastroenterol. Apr. 1993;88(4):564-9. Not eligible target population. [pmid: 8385881].
1915 Obedian E, Haffty BG. Breast conserving therapy in breast cancer patients presenting with nipple discharge. Int J Radiat Oncol Biol Phys. Apr. 1. 2000;47(1):137-42. Not eligible level of evidence. [pmid: 10758315].
1916 Obenauer S, Sohns C, Werner C, et al. Computer-aided detection in full-field digital mammography: detection in dependence of the BI-RADS categories. Breast J. Jan–Feb. 2006;12(1):16-9. Not eligible outcomes. [pmid: 16409582].
1917 Obenauer S, Sohns C, Werner C, et al. Impact of breast density on computer-aided detection in full-field digital mammography. J Digit Imaging. Sep. 2006;19(3):258-63. Not eligible outcomes. [pmid: 16741664].
1918 Oberman HA. Invasive carcinoma of the breast with granulomatous response. Am J Clin Pathol. Dec. 1987;88(6):718-21. Case Reports. [pmid: 2825512].
1919 O’Brien W, Hasselgren PO, Hummel RP, et al. Comparison of postoperative wound complications and early cancer recurrence between patients undergoing mastectomy with or without immediate breast reconstruction. Am J Surg. Jul. 1993;166(1):1-5. Not eligible outcomes. [pmid: 8392300].
1920 O’Connor MK, Phillips SW, Hruska CB, et al. Molecular breast imaging: advantages and limitations of a scintimammographic technique in patients with small breast tumors. Breast J. Jan–Feb. 2007;13(1):3-11. Not eligible outcomes. [pmid: 17214787].
1921 O’Donnell ME, Salem A, Badger SA, et al. Completion mastectomy after breast conserving surgery. Breast. Apr. 2008;17(2):199-204. Not eligible exposure. [pmid: 18024117].
1922 Oertel YC, Galblum LI. Fine needle aspiration of the breast: diagnostic criteria. Pathol Annu. 1983;18(Pt 1):375-407. Not eligible outcomes. [pmid: 6308547].
1923 O’Flynn EA, Morel JC, Gonzalez J, et al. Prediction of the presence of invasive disease from the measurement of extent of malignant microcalcification on mammography and ductal carcinoma in situ grade at core biopsy. Clin Radiol. Feb. 2009;64(2):178-83. Not eligible outcomes. [pmid: 19103348].
1924 O’Grady TC, Robbins BA, Barrett TL, et al. Subcutaneous cysticercosis simulating metastatic breast carcinoma. Int J Dermatol. Jan. 1993;32(1):62-4. Case Reports. [pmid: 8381116].
1925 Oh DK, Kim SH, Choi SH, et al. Intraductal tubular carcinoma of the pancreas: a case report with the imaging findings. Korean J Radiol. Sep–Oct. 2008;9(5):473-6. Not eligible target population. [pmid: 18838860].
1926 Oh YL, Choi JS, Song SY, et al. Expression of p21Waf1, p27Kip1 and cyclin D1 proteins in breast ductal carcinoma in situ: Relation with clinicopathologic characteristics and with p53 expression and estrogen receptor status. Pathol Int. Feb. 2001;51(2):94-9. Not eligible outcomes. [pmid: 11169147].
1927 Ohanaka CE, Ollu-Eddo AN. Paget’s disease of the nipple-areola complex as seen in Benin City, Nigeria. Niger J Clin Pract. Dec. 2006;9(2):179-82. Not eligible target population. [pmid: 17319355].
1928 Ohara M, Yamaguchi Y, Matsuura K, et al. Possible involvement of regulatory T cells in tumor onset and progression in primary breast cancer. Cancer Immunol Immunother. Mar. 2009;58(3):441-7. Not eligible outcomes. [pmid: 18685848].
1929 Ohta T, Nagakawa T, Tsukioka Y, et al. Expression of argyrophilic nucleolar organizer regions in ductal adenocarcinoma of the pancreas and its relationship to prognosis. Int J Pancreatol. Jun. 1993;13(3):193-200. Not eligible target population. [pmid: 8396611].
1930 Ohtake T, Abe R, Kimijima I, et al. Intraductal extension of primary invasive breast carcinoma treated by breast-conservative surgery. Computer graphic three-dimensional reconstruction of the mammary duct-lobular systems. Cancer. Jul. 1. 1995;76(1):32-45. Not eligible target population. [pmid: 8630874].
1931 Ohtake T, Kimijima I, Fukushima T, et al. Computer-assisted complete three-dimensional reconstruction of the mammary ductal/lobular systems: implications of ductal anastomoses for breast-conserving surgery. Cancer. Jun. 15. 2001;91(12):2263-72. Case Reports. [pmid: 11413514].
1932 Ohuchi N, Furuta A, Mori S. Management of ductal carcinoma in situ with nipple discharge. Intraductal spreading of carcinoma is an unfavorable pathologic factor for breast-conserving surgery. Cancer. Aug. 15. 1994;74(4):1294-302. Not eligible outcomes. [pmid: 8055451].
1933 Ohuchi N, Yoshida K, Kimura M, et al. Improved detection rate of early breast cancer in mass screening combined with mammography. Jpn J Cancer Res. Jul. 1993;84(7):807-12. Not eligible outcomes. [pmid: 8396569].
1934 Ojima H, Kanai Y, Iwasaki M, et al. Intraductal carcinoma component as a favorable prognostic factor in biliary tract carcinoma. Cancer Sci. Jan. 2009;100(1):62-70. Not eligible target population. [pmid: 19038006].
1935 Okita A, Ohsumi S, Takashima S, et al. Non-palpable ductal carcinoma in situ (DCIS) with microinvasion arising in a radial scar presenting with spiculation alone on mammograms: a case report. Breast Cancer. 2006;13(1):107-11. Case Reports. [pmid: 16518071].
1936 Okuda M, Yokomise H, Chang SS, et al. Mediastinal metastasis of the thyroid papillary carcinoma mimicking thymoma. Gen Thorac Cardiovasc Surg. Oct. 2008;56(10):518-20. Case Reports. [pmid: 18854931].
1937 Okumura Y, Yamamoto Y, Zhang Z, et al. Identification of biomarkers in ductal carcinoma in situ of the breast with microinvasion. BMC Cancer. 2008;8:287. Not eligible outcomes. [pmid: 18837981].
1938 Olewniczak S, Chosia M, Kolodziej B, et al. Angiogenesis as determined by computerised image analysis and the risk of early relapse in women with invasive ductal breast carcinoma. Pol J Pathol. 2003;54(1):53-9. Not eligible target population. [pmid: 12817881].
1939 Olive PL, Durand RE, Le Riche J, et al. Gel electrophoresis of individual cells to quantify hypoxic fraction in human breast cancers. Cancer Res. Feb. 15. 1993;53(4):733-6. Not eligible exposure. [pmid: 8381327].
1940 Oliveira VM, Piato S, Silva MA. Correlation of cyclooxygenase-2 and aromatase immunohistochemical expression in invasive ductal carcinoma, ductal carcinoma in situ, and adjacent normal epithelium. Breast Cancer Res Treat. Feb. 2006;95(3):235-41. Not eligible outcomes. [pmid: 16322898].
1941 Olson JE, Ingle JN, Ma CX, et al. A comprehensive examination of CYP19 variation and risk of breast cancer using two haplotype-tagging approaches. Breast Cancer Res Treat. Apr. 2007;102(2):237-47. Not eligible outcomes. [pmid: 17004113].
1942 Olson TP, Harter J, Munoz A, et al. Frozen section analysis for intraoperative margin assessment during breast-conserving surgery results in low rates of re-excision and local recurrence. Ann Surg Oncol. Oct. 2007;14(10):2953-60. Not eligible target population. [pmid: 17674109].
1943 O’Malley FP, Saad Z, Kerkvliet N, et al. The predictive power of semiquantitative immunohistochemical assessment of p53 and c-erb B-2 in lymph node-negative breast cancer. Hum Pathol. Sep. 1996;27(9):955-63. Not eligible outcomes. [pmid: 8816892].
1944 O’Malley FP, Vnencak-Jones CL, Dupont WD, et al. p53 mutations are confined to the comedo type ductal carcinoma in situ of the breast. Immunohistochemical and sequencing data. Lab Invest. Jul. 1994;71(1):67-72. Not eligible outcomes. [pmid: 8041120].
1945 Opie H, Estes NC, Jewell WR, et al. Breast biopsy for nonpalpable lesions: a worthwhile endeavor. Am Surg. Aug. 1993;59(8):490-3. discussion 3-4. Not eligible outcomes. [pmid: 8393310].
1946 Orel SG, Dougherty CS, Reynolds C, et al. MR imaging in patients with nipple discharge: initial experience. Radiology. Jul. 2000;216(1):248-54. Not eligible outcomes. [pmid: 10887256].
1947 Orel SG, Mendonca MH, Reynolds C, et al. MR imaging of ductal carcinoma in situ. Radiology. Feb. 1997;202(2):413-20. Not eligible level of evidence. [pmid: 9015067].
1948 Orel SG, Rosen M, Mies C, et al. MR imaging-guided 9-gauge vacuum-assisted core-needle breast biopsy: initial experience. Radiology. Jan. 2006;238(1):54-61. Not eligible exposure. [pmid: 16304093].
1949 Orel SG, Schnall MD, Newman RW, et al. MR imaging-guided localization and biopsy of breast lesions: initial experience. Radiology. Oct. 1994;193(1):97-102. Not eligible exposure. [pmid: 8090928].
1950 Orel SG, Troupin RH, Patterson EA, et al. Breast cancer recurrence after lumpectomy and irradiation: role of mammography in detection. Radiology. Apr. 1992;183(1):201-6. Not eligible target population. [pmid: 1312733].
1951 Orsetti B, Courjal F, Cuny M, et al. 17q21–q25 aberrations in breast cancer: combined allelotyping and CGH analysis reveals 5 regions of allelic imbalance among which two correspond to DNA amplification. Oncogene. Nov. 4. 1999;18(46):6262-70. Not eligible outcomes. [pmid: 10597224].
1952 Orta L, Suprun U, Goldfarb A, et al. Radiation-associated extraskeletal osteosarcoma of the chest wall. Arch Pathol Lab Med. Feb. 2006;130(2):198-200. Case Reports. [pmid: 16454562].
1953 Osako T, Takahashi K, Iwase T, et al. Diagnostic ultrasonography and mammography for invasive and noninvasive breast cancer in women aged 30 to 39 years. Breast Cancer. 2007;14(2):229-33. Not eligible outcomes. [pmid: 17485910].
1954 Osborne CK, Pippen J, Jones SE, et al. Double-blind, randomized trial comparing the efficacy and tolerability of fulvestrant versus anastrozole in postmenopausal women with advanced breast cancer progressing on prior endocrine therapy: results of a North American trial. J Clin Oncol. Aug. 15. 2002;20(16):3386-95. Not eligible target population. [pmid: 12177098].
1955 O’Shaughnessy J. A decade of letrozole: FACE. Breast Cancer Res Treat. 2007;105(Suppl 1):67-74. Not eligible target population. [pmid: 17912637].
1956 Oshida K, Nagashima T, Ueda T, et al. Pharmacokinetic analysis of ductal carcinoma in situ of the breast using dynamic MR mammography. Eur Radiol. Jul. 2005;15(7):1353-60. Not eligible outcomes. [pmid: 15789211].
1957 Osin P, Gusterson BA, Philp E, et al. Predicted anti-oestrogen resistance in BRCA-associated familial breast cancers. Eur J Cancer. Oct. 1998;34(11):1683-6. Not eligible outcomes. [pmid: 9893652].
1958 Ostashkin AS, Malivanova TF, Iurchenko VA, et al. Tumor necrosis factor gene polymorphisms in breast cancer patients. Genetika. Sep. 2008;44(9):1275-80. Language. [pmid: 18846826].
1959 O’Sullivan MJ, Li T, Freedman G, et al. The effect of multiple reexcisions on the risk of local recurrence after breast conserving surgery. Ann Surg Oncol. Nov. 2007;14(11):3133-40. Not eligible outcomes. [pmid: 17653798].
1960 Otsuki Y, Yamada M, Shimizu S, et al. Solid-papillary carcinoma of the breast: clinicopathological study of 20 cases. Pathol Int. Jul. 2007;57(7):421-9. Not eligible outcomes. [pmid: 17587241].
1961 Ottesen GL, Christensen IJ, Larsen JK, et al. Flow cytometric DNA analysis of breast cancers with predominance of carcinoma in situ: a comparison of the premalignant and malignant components. Clin Cancer Res. Aug. 1995;1(8):881-8. Not eligible outcomes. [pmid: 9816058].
1962 Ottesen GL, Graversen HP, Blichert-Toft M, et al. Lobular carcinoma in situ of the female breast. Short-term results of a prospective nationwide study. The Danish Breast Cancer Cooperative Group. Am J Surg Pathol. Jan. 1993;17(1):14-21. Not eligible target population. [pmid: 8383466].
1963 Ottinetti A, Sapino A. Morphometric evaluation of microvessels surrounding hyperplastic and neoplastic mammary lesions. Breast Cancer Res Treat. Jul. 1988;11(3):241-8. Not eligible outcomes. [pmid: 2458784].
1964 Owaki T, Kijima Y, Yoshinaka H, et al. Ductal carcinoma in-situ of the breast detected by [F-18] fluorodeoxyglucose positron emission tomography. Breast Cancer. 2006;13(2):210-3. Case Reports. [pmid: 16755120].
1965 Owings DV, Hann L, Schnitt SJ. How thoroughly should needle localization breast biopsies be sampled for microscopic examination? A prospective mammographic/pathologic correlative study. Am J Surg Pathol. Jun. 1990;14(6):578-83. Not eligible outcomes. [pmid: 2337206].
1966 Ozaki S, Tozaki M, Fukuma E, et al. Bilateral breast MR imaging: is it superior to conventional methods for the detection of contralateral breast cancer. Breast Cancer. 2008;15(2):169-74. Not eligible outcomes. [pmid: 18317885].
1967 Ozkara SK, Ustun MO, Paksoy N. The gray zone in breast fine needle aspiration cytology. How to report on it?. Acta Cytol. May–Jun. 2002;46(3):513-8. Not eligible outcomes. [pmid: 12040646].
1968 Ozturk M, Bolkent S, Yilmazer S, et al. Detection of c-erbB-2 mRNAs using dig-labelled oligonucleotide probe with in situ hybridisation in human breast carcinoma: comparison with immunohistochemical results. Anal Cell Pathol. 1998;16(4):201-9. Not eligible target population. [pmid: 9762367].
1969 Ozzello L, Gump FE. The management of patients with carcinomas in fibroadenomatous tumors of the breast. Surg Gynecol Obstet. Feb. 1985;160(2):99-104. Not eligible outcomes. [pmid: 2982218].
1970 Padmore RF, Fowble B, Hoffman J, et al. Microinvasive breast carcinoma: clinicopathologic analysis of a single institution experience. Cancer. Mar. 15. 2000;88(6):1403-9. Not eligible level of evidence. [pmid: 10717623].
1971 Padmore RF, Lara JF, Ackerman DJ, et al. Primary combined malignant melanoma and ductal carcinoma of the breast. A report of two cases. Cancer. Dec. 15. 1996;78(12):2515-25. Case Reports. [pmid: 8952560].
1972 Pagani A, Papotti M, Sanfilippo B, et al. Expression of the gastrin-releasing peptide gene in carcinomas of the breast. Int J Cancer. Feb. 1. 1991;47(3):371-5. Not eligible outcomes. [pmid: 1847122].
1973 Page DL, Dupont WD, Rogers LW, et al. Continued local recurrence of carcinoma 15-25 years after a diagnosis of low grade ductal carcinoma in situ of the breast treated only by biopsy. Cancer. Oct. 1. 1995;76(7):1197-200. Not eligible level of evidence. [pmid: 8630897].
1974 Page DL, Dupont WD, Rogers LW, et al. Intraductal carcinoma of the breast: follow-up after biopsy only. Cancer. Feb. 15. 1982;49(4):751-8. Not eligible level of evidence. [pmid: 6275978].
1975 Page DL, Dupont WD, Rogers LW, et al. Atypical hyperplastic lesions of the female breast. A long-term follow-up study. Cancer. Jun. 1. 1985;55(11):2698-708. Not eligible target population. [pmid: 2986821].
1976 Pai VR, Gregory NE, Swinford AE, et al. Ductal carcinoma in situ: computer-aided detection in screening mammography. Radiology. Dec. 2006;241(3):689-94. Not eligible outcomes. [pmid: 17053200].
1977 Palmer BV, Mannur KR, Ross WB. Subcutaneous mastectomy with immediate reconstruction as treatment for early breast cancer. Br J Surg. Dec. 1992;79(12):1309-11. Not eligible target population. [pmid: 1336699].
1978 Palmieri C, Lam EW, Mansi J, et al. The expression of ER beta cx in human breast cancer and the relationship to endocrine therapy and survival. Clin Cancer Res. Apr. 1. 2004;10(7):2421-8. Not eligible outcomes. [pmid: 15073120].
1979 Pandelidis SM, Peters KL, Walusimbi MS, et al. The role of axillary dissection in mammographically detected carcinoma. J Am Coll Surg. Apr. 1997;184(4):341-5. Not eligible outcomes. [pmid: 9100677].
1980 Pandis N, Heim S, Bardi G, et al. Whole-arm t(1;16) and i(1q) as sole anomalies identify gain of 1q as a primary chromosomal abnormality in breast cancer. Genes Chromosomes Cancer. Oct. 1992;5(3):235-8. Case Reports. [pmid: 1384676].
1981 Pandis N, Heim S, Bardi G, et al. Chromosome analysis of 20 breast carcinomas: cytogenetic multiclonality and karyotypic-pathologic correlations. Genes Chromosomes Cancer. Jan. 1993;6(1):51-7. Not eligible outcomes. [pmid: 7680222].
1982 Panico L, D’Antonio A, Salvatore G, et al. Differential immunohistochemical detection of transforming growth factor alpha, amphiregulin and CRIPTO in human normal and malignant breast tissues. Int J Cancer. Jan. 3. 1996;65(1):51-6. Not eligible outcomes. [pmid: 8543395].
1983 Pannuti F, Martoni A, Cilenti G, et al. Adjuvant therapy for operable breast cancer with medroxyprogesterone acetate alone in postmenopausal patients or in combination with CMF in premenopausal patients. Eur J Cancer Clin Oncol. Mar. 1988;24(3):423-9. Not eligible target population. [pmid: 2968262].
1984 Paone JF, Baker RR. Pathogenesis and treatment of Paget’s disease of the breast. Cancer. Aug. 1. 1981;48(3):825-9. Not eligible target population. [pmid: 6265059].
1985 Papantoniou V, Christodoulidou J, Papadaki E, et al. Uptake and washout of 99mTcV-dimercaptosuccinic acid and 99mTc-sestamibi in the assessment of histological type and grade in breast cancer. Nucl Med Commun. May. 2002;23(5):461-7. Not eligible outcomes. [pmid: 11973487].
1986 Papantoniou V, Christodoulidou J, Papadaki E, et al. 99mTc-(V)DMSA scintimammography in the assessment of breast lesions: comparative study with 99mTc-MIBI. Eur J Nucl Med. Jul. 2001;28(7):923-8. Not eligible outcomes. [pmid: 11504092].
1987 Papantoniou V, Sotiropoulou M, Stipsaneli E, et al. Scintimammographic findings of in situ ductal breast carcinoma in a double-phase study with Tc-99m(V) DMSA and Tc-99m MIBI value of Tc-99m(V) DMSA. Clin Nucl Med. Jun. 2000;25(6):434-9. Case Reports. [pmid: 10836691].
1988 Papantoniou V, Tsiouris S, Mainta E, et al. Imaging in situ breast carcinoma (with or without an invasive component) with technetium-99m pentavalent dimercaptosuccinic acid and technetium-99m 2-methoxy isobutyl isonitrile scintimammography. Breast Cancer Res. 2005;7(1):R33-45. Not eligible outcomes. [pmid: 15642168].
1989 Papapolychroniadis C, Kaimakis D, Giannoulis K, et al. Metachronous breast carcinoma (second malignancy), following “cure” from colorectal carcinoma. Tech Coloproctol. Nov. 2004;8(Suppl 1):s129-31. Case Reports. [pmid: 15655596].
1990 Pappo I, Meirshon I, Karni T, et al. The characteristics of malignant breast tumors in hormone replacement therapy users versus nonusers. Ann Surg Oncol. Jan. 2004;11(1):52-8. Not eligible outcomes. [pmid: 14699034].
1991 Paradiso A, Ventrella V, Farchi G, et al. Mammographic aspect, cell kinetics and hormone receptor status of operable breast cancer. Oncology. Mar–Apr. 1993;50(2):104-9. Not eligible outcomes. [pmid: 8383827].
1992 Paredes J, Milanezi F, Viegas L, et al. P-cadherin expression is associated with high-grade ductal carcinoma in situ of the breast. Virchows Arch. Jan. 2002;440(1):16-21. Not eligible outcomes. [pmid: 11942571].
1993 Pargaonkar AS, Beissner RS, Snyder S, et al. Evaluation of immunohistochemistry and multiple-level sectioning in sentinel lymph nodes from patients with breast cancer. Arch Pathol Lab Med. Jun. 2003;127(6):701-5. Not eligible target population. [pmid: 12741893].
1994 Parham DM, Jankowski J. Transforming growth factor alpha in epithelial proliferative diseases of the breast. J Clin Pathol. Jun. 1992;45(6):513-6. Not eligible outcomes. [pmid: 1320636].
1995 Paridaens R, Dirix L, Lohrisch C, et al. Mature results of a randomized phase II multicenter study of exemestane versus tamoxifen as first-line hormone therapy for postmenopausal women with metastatic breast cancer. Ann Oncol. Sep. 2003;14(9):1391-8. Not eligible target population. [pmid: 12954578].
1996 Paridaens R, Heuson JC, Julien JP, et al. Assessment of estrogenic recruitment before chemotherapy in advanced breast cancer: preliminary results of a double-blind randomized study of the EORTC Breast Cancer Cooperative Group. J Steroid Biochem Mol Biol. Dec. 20. 1990;37(6):1109-13. Not eligible target population. [pmid: 2285584].
1997 Paridaens R, Heuson JC, Julien JP, et al. Assessment of estrogenic recruitment before chemotherapy in advanced breast cancer: a double-blind randomized study. European Organization for Research and Treatment of Cancer Breast Cancer Cooperative Group. J Clin Oncol. Sep. 1993;11(9):1723-8. Not eligible target population. [pmid: 8355039].
1998 Park BW, Kim SI, Lee KS, et al. Ductal eccrine carcinoma presenting as a Paget’s disease-like lesion of the breast. Breast J. Sep–Oct. 2001;7(5):358-62. Case Reports. [pmid: 11906447].
1999 Park CC, Mitsumori M, Nixon A, et al. Outcome at 8 years after breast-conserving surgery and radiation therapy for invasive breast cancer: influence of margin status and systemic therapy on local recurrence. J Clin Oncol. Apr. 2000;18(8):1668-75. Not eligible target population. [pmid: 10764427].
2000 Park MJ, Cha ES, Kang BJ, et al. The role of diffusion-weighted imaging and the apparent diffusion coefficient (ADC) values for breast tumors. Korean J Radiol. Sep–Oct. 2007;8(5):390-6. Not eligible outcomes. [pmid: 17923781].
2001 Park SS, Kim JE, Kim YA, et al. Caveolin-1 is down-regulated and inversely correlated with HER2 and EGFR expression status in invasive ductal carcinoma of the breast. Histopathology. Dec. 2005;47(6):625-30. Not eligible outcomes. [pmid: 16324201].
2002 Park SY, Kim EK, Oh KK, et al. The role of sonography in patients with breast cancer presenting as an axillary mass. Korean J Radiol. Jul–Sep. 2002;3(3):189-93. Not eligible outcomes. [pmid: 12271164].
2003 Partanen S. Histochemistry of estrogen sulfatases in human breast diseases. Virchows Arch B Cell Pathol Incl Mol Pathol. 1985;49(1):53-60. Not eligible outcomes. [pmid: 2862735].
2004 Partridge A, Adloff K, Blood E, et al. Risk perceptions and psychosocial outcomes of women with ductal carcinoma in situ: longitudinal results from a cohort study. J Natl Cancer Inst. Feb. 20. 2008;100(4):243-51. Not association hypothesis tested. [pmid: 18270338].
2005 Partridge A, Winer JP, Golshan M, et al. Perceptions and management approaches of physicians who care for women with ductal carcinoma in situ. Clinical Breast Cancer. Jun. 2008;8(3):275-80. Not eligible outcomes. [pmid: 18650159].
2006 Partridge AH, Wong JS, Knudsen K, et al. Offering participants results of a clinical trial: sharing results of a negative study. Lancet. Mar. 12–18. 2005;365(9463):963-4. Not eligible outcomes. [pmid: 15766998].
2007 Pastakia B, Chang V, McDonald H, et al. Immediate postexcision mammography for occult noncalcified breast lesions. South Med J. Jan. 1990;83(1):30-3. Not eligible outcomes. [pmid: 2154038].
2008 Pasternack T, Shaco-Levy R, Wiznitzer A, et al. Extraovarian pelvic yolk sac tumor: case report and review of published work. J Obstet Gynaecol Res. Aug. 2008;34(4 Pt 2):739-44. Case Reports. [pmid: 18840194].
2009 Patchefsky AS, Schwartz GF, Finkelstein SD, et al. Heterogeneity of intraductal carcinoma of the breast. Cancer. Feb. 15. 1989;63(4):731-41. Not eligible outcomes. [pmid: 2536585].
2010 Patel NP, Bergman S, Geisinger KR. Fine-needle aspiration biopsy cytology of cutaneous calcinosis in a 74-year-old woman with dermatomyositis on methotrexate therapy: a case report. Acta Cytol. Jul–Aug. 2008;52(4):454-8. Not eligible target population. [pmid: 18702364].
2011 Patla A, Rudnicka-Sosin L, Pawlega J, et al. Prognostic significance of selected immunohistochemical parameters in patients with invasive breast carcinoma concomitant with ductal carcinoma in situ. Pol J Pathol. 2002;53(1):25-7. Not eligible outcomes. [pmid: 12014222].
2012 Patterson SK, Joe A, Helvie MA. Sonographically-guided metallic marker placement at time of wire localization for intraductal or cystic lesions: a method to verify lesion retrieval. Acad Radiol. Oct. 2008;15(10):1316-21. Not eligible outcomes. [pmid: 18790404].
2013 Patton ML, Haith LR Jr, Goldman WT. An improved technique for needle localized biopsy of occult lesions of the breast. Surg Gynecol Obstet. Jan. 1993;176(1):25-9. Not eligible outcomes. [pmid: 8381241].
2014 Pavelic ZP, Pavelic K, Carter CP, et al. Heterogeneity of c-myc expression in histologically similar infiltrating ductal carcinomas of the breast. J Cancer Res Clin Oncol. 1992;118(1):16-22. Not eligible outcomes. [pmid: 1309531].
2015 Pavelic ZP, Steele P, Preisler HD. Evaluation of c-myc proto-oncogene in primary human breast carcinomas. Anticancer Res. Jul–Aug. 1991;11(4):1421-7. Not eligible outcomes. [pmid: 1660688].
2016 Pawlik TM, Perry A, Strom EA, et al. Potential applicability of balloon catheter-based accelerated partial breast irradiation after conservative surgery for breast carcinoma. Cancer. Feb. 1. 2004;100(3):490-8. Not eligible outcomes. [pmid: 14745864].
2017 Pediconi F, Occhiato R, Venditti F, et al. Radial scars of the breast: contrast-enhanced magnetic resonance mammography appearance. Breast J. Jan–Feb. 2005;11(1):23-8. Not eligible level of evidence. [pmid: 15647074].
2018 Peelen T, de Leeuw W, van Lent K, et al. Genetic analysis of a breast-ovarian cancer family, with 7 cases of colorectal cancer linked to BRCA1, fails to support a role for BRCA1 in colorectal tumorigenesis. Int J Cancer. Dec. 1. 2000;88(5):778-82. Not eligible outcomes. [pmid: 11072248].
2019 Peison B, Benisch B. Paget’s disease of the nipple simulating malignant melanoma in a black woman. Am J Dermatopathol. 1985;7(Suppl):165-9. Not eligible target population. [pmid: 2856457].
2020 Peltecu G. Images in clinical medicine. Cellulitis after treatment for breast cancer. N Engl J Med. Aug. 2. 2007;357(5):488. Case Reports. [pmid: 17671257].
2021 Pena Ayon AR, Mainero Ratchelous FE, Vargas Solano JM, et al. Identification of surgical margins by intraoperative mammography of quadrantectomys specimens for breast cancer and histopathological comparison. Ginecol Obstet Mex. Oct. 2007;75(10):588-602. Language. [pmid: 18800577].
2022 Pendleton N, Pazouki S, Heerkens E, et al. Relationships between different measurements of vascularity and clinico-pathological parameters in breast cancer. Anticancer Res. Nov–Dec. 1998;18(6B):4565-8. Not eligible outcomes. [pmid: 9891519].
2023 Pennisi VR. Timing of breast reconstruction after mastectomy. Clin Plast Surg. Jan. 1979;6(1):31-6. Not eligible outcomes. [pmid: 221147].
2024 Pennisi VR. Obscure carcinoma encountered in subcutaneous mastectomy in silicone- and paraffin-injected breasts: two patients. Plast Reconstr Surg. Oct. 1984;74(4):535-8. Case Reports. [pmid: 6091166].
2025 Pereira MB, Dias AJ, Reis CA, et al. Immunohistochemical study of the expression of MUC5AC and MUC6 in breast carcinomas and adjacent breast tissues. J Clin Pathol. Mar. 2001;54(3):210-3. Not eligible outcomes. [pmid: 11253133].
2026 Perera F, Yu E, Engel J, et al. Patterns of breast recurrence in a pilot study of brachytherapy confined to the lumpectomy site for early breast cancer with six years’ minimum follow-up. Int J Radiat Oncol Biol Phys. Dec. 1. 2003;57(5):1239-46. Not eligible target population. [pmid: 14630257].
2027 Perez Carrion R, Alberola Candel V, Calabresi F, et al. Comparison of the selective aromatase inhibitor formestane with tamoxifen as first-line hormonal therapy in postmenopausal women with advanced breast cancer. Ann Oncol. 1994;5(Suppl 7):S19-24. Not eligible target population. [pmid: 7873457].
2028 Perez EA, Josse RG, Pritchard KI, et al. Effect of letrozole versus placebo on bone mineral density in women with primary breast cancer completing 5 or more years of adjuvant tamoxifen: a companion study to NCIC CTG MA.17. J Clin Oncol. Aug. 1. 2006;24(22):3629-35. Not eligible target population. [pmid: 16822845].
2029 Perin T, Canzonieri V, Massarut S, et al. Immunohistochemical evaluation of multiple biological markers in ductal carcinoma in situ of the breast. Eur J Cancer. Jun. 1996;32A(7):1148-55. Not eligible outcomes. [pmid: 8758245].
2030 Perkins RS, Sahm K, Marando C, et al. Analysis of Epstein-Barr virus reservoirs in paired blood and breast cancer primary biopsy specimens by real time PCR. Breast Cancer Res. 2006;8(6):R70. Not eligible outcomes. [pmid: 17163997].
2031 Perlet C, Schneider P, Amaya B, et al. MR-Guided vacuum biopsy of 206 contrast-enhancing breast lesions. Rofo. Jan. 2002;174(1):88-95. Not eligible outcomes. [pmid: 11793291].
2032 Perre CI, Hoynck van Papendrecht AA, Sierink HD, et al. The non-palpable, radiographically suspicious breast lesion: an analysis of 101 cases. Neth J Surg. Jun. 1990;42(3):69-71. Not eligible outcomes. [pmid: 2164172].
2033 Perretta T, Pistolese CA, Bolacchi F, et al. MR imaging-guided 10-gauge vacuum-assisted breast biopsy: histological characterisation. Radiologia Medica. Sep. 2008;113(6):830-40. Not eligible exposure. [pmid: 18633687].
2034 Perri P, Brienza D, Mazzeo V, et al. Orbital metastases: echographic findings our experience. Ophthalmologica. 1998;212(Suppl 1):82-4. Not eligible outcomes. [pmid: 9730761].
2035 Perrone G, Santini D, Vincenzi B, et al. COX-2 expression in DCIS: correlation with VEGF, HER-2/neu, prognostic molecular markers and clinicopathological features. Histopathology. May. 2005;46(5):561-8. Not eligible outcomes. [pmid: 15842638].
2036 Perrone G, Zagami M, Santini D, et al. COX-2 expression in lobular in situ neoplasia of the breast: correlation with histopathological grading system according to the Tavassoli classification. Histopathology. Jul. 2007;51(1):33-9. Not eligible outcomes. [pmid: 17542993].
2037 Perzin KH, Lattes R. Papillary adenoma of the nipple (florid papillomatosis, adenoma, adenomatosis). A clinicopathologic study. Cancer. Apr. 1972;29(4):996-1009. Not eligible target population. [pmid: 4335982].
2038 Pesce C, Reale A, Sementa A, et al. Nuclear diameters in the invasive ductal carcinoma of the breast with a predominant intraductal component. Verh Dtsch Ges Pathol. 1985;69:376-9. Not eligible target population. [pmid: 3006388].
2039 Pestalozzi BC, Sotos GA, Choyke PL, et al. Typhlitis resulting from treatment with taxol and doxorubicin in patients with metastatic breast cancer. Cancer. Mar. 1. 1993;71(5):1797-800. Case Reports. [pmid: 8095437].
2040 Pesutic-Pisac V, Bezic J, Tomic S. Collagenous spherulosis of the breast in association with in situ carcinoma. Pathologica. Dec. 2002;94(6):317-9. Case Reports. [pmid: 12540997].
2041 Peters G, Anderson J, Longman G, et al. Magnetic resonance findings in women at high risk for developing breast cancer: an Australian feasibility study. J Med Imaging Radiat Oncol. Feb. 2008;52(1):29-35. Not eligible level of evidence. [pmid: 18373823].
2042 Peters N, Hoorntje L, Mali W, et al. Diagnostic performance of stereotactic large core needle biopsy for nonpalpable breast lesions in routine clinical practice. International Journal of Cancer. Jan. 15. 2008;122(2):468-71. Not eligible exposure.
2043 Petit JY, Veronesi U, Orecchia R, et al. Nipple-sparing mastectomy in association with intra operative radiotherapy (ELIOT): A new type of mastectomy for breast cancer treatment. Breast Cancer Res Treat. Mar. 2006;96(1):47-51. Not eligible target population. [pmid: 16261402].
2044 Petit JY, Veronesi U, Orecchia R, et al. The nipple-sparing mastectomy: early results of a feasibility study of a new application of perioperative radiotherapy (ELIOT) in the treatment of breast cancer when mastectomy is indicated. Tumori. May–Jun. 2003;89(3):288-91. Not eligible outcomes. [pmid: 12908785].
2045 Petrek J, Rosen PP, Robbins GF. Carcinoma of aberrant breast tissue. Clin Bull. 1980;10(1):13-5. Case Reports. [pmid: 6248267].
2046 Petrik DW, McCready DR, Goel V, et al. The rate of breast-conserving surgery for early breast cancer is not influenced by the surgical strategy of excisional biopsy followed by the definitive procedure. Breast J. May–Jun. 2001;7(3):158-65. Not eligible target population. [pmid: 11469928].
2047 Petrovich JA, Ross DS, Sullivan JW, et al. Mammographic wire localization in diagnosis and treatment of occult carcinoma of breast. Surg Gynecol Obstet. Mar. 1989;168(3):239-43. Not eligible outcomes. [pmid: 2537536].
2048 Pezzi CM, Kukora JS, Audet IM, et al. Breast conservation surgery using nipple-areolar resection for central breast cancers. Arch Surg. Jan. 2004;139(1):32-7. discussion 8. Not eligible target population. [pmid: 14718272].
2049 Pfleiderer SO, Freesmeyer MG, Marx C, et al. Cryotherapy of breast cancer under ultrasound guidance: initial results and limitations. Eur Radiol. Dec. 2002;12(12):3009-14. Not eligible target population. [pmid: 12439583].
2050 Pfleiderer SO, Marx C, Camara O, et al. Ultrasound-guided, percutaneous cryotherapy of small (< or = 15 mm) breast cancers. Invest Radiol. Jul. 2005;40(7):472-7. Not eligible target population. [pmid: 15973140].
2051 Pfleiderer SO, Marx C, Vagner J, et al. Magnetic resonance-guided large-core breast biopsy inside a 1.5-T magnetic resonance scanner using an automatic system: in vitro experiments and preliminary clinical experience in four patients. Invest Radiol. Jul. 2005;40(7):458-63. Not eligible exposure. [pmid: 15973138].
2052 Phelan S, O’Doherty A, Hill A, et al. Epithelial displacement during breast needle core biopsy causes diagnostic difficulties in subsequent surgical excision specimens. J Clin Pathol. Apr. 2007;60(4):373-6. Case Reports. [pmid: 16822879].
2053 Philpotts LE, Shaheen NA, Jain KS, et al. Uncommon high-risk lesions of the breast diagnosed at stereotactic core-needle biopsy: clinical importance. Radiology. Sep. 2000;216(3):831-7. Not eligible outcomes. [pmid: 10966718].
2054 Piekarski J, Jeziorski A, Baklinska M, et al. Patients with Paget disease of nipple and with palpable mass in breast have unfavorable prognosis. J Exp Clin Cancer Res. Mar. 2004;23(1):33-7. Not eligible target population. [pmid: 15149148].
2055 Pienta KJ, Coffey DS. Correlation of nuclear morphometry with progression of breast cancer. Cancer. Nov. 1. 1991;68(9):2012-6. Not eligible target population. [pmid: 1655233].
2056 Pierce LJ, Haffty BG, Solin LJ, et al. The conservative management of Paget’s disease of the breast with radiotherapy. Cancer. Sep. 15. 1997;80(6):1065-72. Not eligible target population. [pmid: 9305706].
2057 Pierce LJ, Moughan J, White J, et al. 1998-1999 patterns of care study process survey of national practice patterns using breast-conserving surgery and radiotherapy in the management of stage I–II breast cancer. Int J Radiat Oncol Biol Phys. May. 1. 2005;62(1):183-92. Not eligible target population. [pmid: 15850920].
2058 Pijnappel RM, van Dalen A, Borel Rinkes IH, et al. The diagnostic accuracy of core biopsy in palpable and non-palpable breast lesions. Eur J Radiol. Feb. 1997;24(2):120-3. Not eligible outcomes. [pmid: 9097053].
2059 Pijnappel RM, van den Donk M, Holland R, et al. Diagnostic accuracy for different strategies of image-guided breast intervention in cases of nonpalpable breast lesions. Br J Cancer. Feb. 9. 2004;90(3):595-600. Not eligible outcomes. [pmid: 14760370].
2060 Pilichowska M, Kimura N, Fujiwara H, et al. Immunohistochemical study of TGF-alpha, TGF-beta1, EGFR, and IGF-1 expression in human breast carcinoma. Mod Pathol. Oct. 1997;10(10):969-75. Not eligible outcomes. [pmid: 9346175].
2061 Pina Insausti LJ, Soga Garcia E. Mucinous breast carcinoma showing as a cluster of suspicious microcalcifications on mammography. Eur Radiol. 1998;8(9):1666-8. Case Reports. [pmid: 9866783].
2062 Pinero A, Galindo PJ, Illana J, et al. Diagnostic efficiency of sestamibi gammagraphy and Doppler sonography in the preoperative assessment of breast lesions. Clin Transl Oncol. Feb. 2006;8(2):103-7. Not eligible outcomes. [pmid: 16632424].
2063 Pisano ED, Johnston RE, Chapman D, et al. Human breast cancer specimens: diffraction-enhanced imaging with histologic correlation--improved conspicuity of lesion detail compared with digital radiography. Radiology. Mar. 2000;214(3):895-901. Not eligible outcomes. [pmid: 10715065].
2064 Pitre B, Baron PL, Baron LF, et al. Stereotactic core biopsy of the breast: results of one-year follow-up of 101 patients. Am Surg. Dec. 1997;63(12):1124-7. Not eligible outcomes. [pmid: 9393264].
2065 Plastaras JP, Harris EE, Solin LJ. Paget’s disease of the nipple as local recurrence after breast-conservation treatment for early-stage breast cancer. Clin Breast Cancer. Oct. 2005;6(4):349-53. Case Reports. [pmid: 16277886].
2066 Plowman PN, Gilmore OJ, Curling M, et al. Paget’s disease of the nipple occurring after conservation management of early infiltrating breast cancer. Br J Surg. Jan. 1986;73(1):45. Not eligible target population. [pmid: 3004626].
2067 Pocock B, Nash S, Klein L, et al. Disparities in time to definitive surgical treatment between black and white women diagnosed with ductal carcinoma in situ. Am J Surg. Oct. 2007;194(4):521-3. Not eligible outcomes. [pmid: 17826071].
2068 Poellinger A, Diekmann S, Dietz E, et al. In patients with DCIS: is it sufficient to histologically examine only those tissue specimens that contain microcalcifications?. European radiology. May. 2008;18(5):925-30. Not eligible outcomes. [pmid: 18183402].
2069 Polgar C, Orosz Z, Kahan Z, et al. Combined surgery and radiotherapy in the treatment of ductal carcinoma in situ of the breast: preliminary results of the Hungarian multicenter prospective randomised study. Magy Onkol. Sep. 2008;52(3):269-77. Language. [pmid: 18845497].
2070 Polito E, Pichierri P, Occhini R, et al. Orbital metastasis associated with primary breast carcinoma in a man detected during peribulbar anesthesia for cataract surgery. Eur J Ophthalmol. Nov–Dec. 2008;18(6):1031-3. Not eligible target population. [pmid: 18988185].
2071 Poller DN, Hutchings CE, Galea M, et al. p53 protein expression in human breast carcinoma: relationship to expression of epidermal growth factor receptor, c-erbB-2 protein overexpression, and oestrogen receptor. Br J Cancer. Sep. 1992;66(3):583-8. Not eligible outcomes. [pmid: 1355662].
2072 Poller DN, Snead DR, Roberts EC, et al. Oestrogen receptor expression in ductal carcinoma in situ of the breast: relationship to flow cytometric analysis of DNA and expression of the c-erbB-2 oncoprotein. Br J Cancer. Jul. 1993;68(1):156-61. Not eligible outcomes. [pmid: 8100443].
2073 Polyak K. Is p53 a breast cancer gene. Cancer Biol Ther. Jan–Feb. 2002;1(1):37-8. Comment. [pmid: 12197482].
2074 Polychronis A, Sinnett HD, Hadjiminas D, et al. Preoperative gefitinib versus gefitinib and anastrozole in postmenopausal patients with oestrogen-receptor positive and epidermal-growth-factor-receptor-positive primary breast cancer: a double-blind placebo-controlled phase II randomised trial. Lancet Oncol. Jun. 2005;6(6):383-91. Not eligible target population. [pmid: 15925816].
2075 Ponti A, Mano MP, Distante V, et al. Audit system on quality of breast cancer diagnosis and treatment (QT): results from the survey on screen-detected lesions in Italy, 2004. Epidemiol Prev. Mar–Jun. 2007;31(2-3 Suppl 2):69-75. Not eligible outcomes. [pmid: 17824364].
2076 Ponti A, Mano MP, Distante V, et al. Audit system on Quality of breast cancer diagnosis and Treatment (QT): results from the survey on screen-detected lesions in Italy, 2003-2004. Epidemiol Prev. Jan–Feb. 2006;30(1 Suppl 3):59-63. Not eligible outcomes.
2077 Ponzone R, Dominguez A, Marra V, et al. Pathological classification of ductal carcinoma in situ of the breast correlates with surgical treatment and may be predicted by mammography. Breast. Oct. 2007;16(5):495-502. Not eligible outcomes. [pmid: 17507226].
2078 Poole GH, Willsher PC, Pinder SE, et al. Diagnosis of breast cancer with core-biopsy and fine needle aspiration cytology. Aust N Z J Surg. Sep. 1996;66(9):592-4. Not eligible outcomes. [pmid: 8859156].
2079 Popanda O, Ebbeler R, Twardella D, et al. Radiation-induced DNA damage and repair in lymphocytes from breast cancer patients and their correlation with acute skin reactions to radiotherapy. Int J Radiat Oncol Biol Phys. Apr. 1. 2003;55(5):1216-25. Not eligible target population. [pmid: 12654430].
2080 Popiela TJ, Sikora J, Klimek M, et al. The analysis of CD34 antigen immunoreactivity level in invasive ductal breast cancer with respect to the presence of lymph node metastases. Neuro Endocrinol Lett. Aug. 2008;29(4):443-6. Not eligible target population. [pmid: 18766141].
2081 Poplack SP, Wells WA. Ductal carcinoma in situ of the breast: mammographic-pathologic correlation. AJR Am J Roentgenol. Jun. 1998;170(6):1543-9. Comment. [pmid: 9609171].
2082 Popnikolov NK, Cavone SM, Schultz PM, et al. Diagnostic utility of p75 neurotrophin receptor (p75NTR) as a marker of breast myoepithelial cells. Mod Pathol. Dec. 2005;18(12):1535-41. Not eligible outcomes. [pmid: 16258511].
2083 Porembka MR, Abraham RL, Sefko JA, et al. Factors Associated with Lymph Node Assessment in Ductal Carcinoma in situ: Analysis of 1988-2002 Seer Data. Ann Surg Oncol. 2008. May. 16. Not eligible outcomes.
2084 Pors H, von Eyben FE, Sorensen OS, et al. Longterm remission of multiple brain metastases with tamoxifen. J Neurooncol. Apr. 1991;10(2):173-7. Case Reports. [pmid: 1716670].
2085 Port ER, Park A, Borgen PI, et al. Results of MRI screening for breast cancer in high-risk patients with LCIS and atypical hyperplasia. Ann Surg Oncol. Mar. 2007;14(3):1051-7. Not eligible target population. [pmid: 17206485].
2086 Porta C, Casagranda I, Semino G, et al. Chronic myeloid leukemia following cyclophosphamide-containing chemotherapy in a breast cancer patient. Haematologica. Jan–Feb. 1993;78(1):56-7. Case Reports. [pmid: 8387943].
2087 Porter D, Lahti-Domenici J, Keshaviah A, et al. Molecular markers in ductal carcinoma in situ of the breast. Mol Cancer Res. Mar. 2003;1(5):362-75. Not eligible outcomes. [pmid: 12651909].
2088 Porter DA, Krop IE, Nasser S, et al. A SAGE (serial analysis of gene expression) view of breast tumor progression. Cancer Res. Aug. 1. 2001;61(15):5697-702. Not eligible outcomes. [pmid: 11479200].
2089 Potter R, Gnant M, Kwasny W, et al. Lumpectomy plus tamoxifen or anastrozole with or without whole breast irradiation in women with favorable early breast cancer. Int J Radiat Oncol Biol Phys. Jun. 1. 2007;68(2):334-40. Not eligible target population. [pmid: 17363187].
2090 Powles TJ, Coombes RC, Smith IE, et al. A double blind randomised clinical trial of adjuvant aminoglutethimide versus placebo given to post menopausal patients with histologically confirmed stage II breast cancer. Breast Cancer Res Treat. 1986;7(Suppl):S37-40. Not eligible target population. [pmid: 3527305].
2091 Powles TJ, Gordon C, Coombes RC. Clinical trial of multiple endocrine therapy for metastatic and locally advanced breast cancer with tamoxifen-aminoglutethimide-danazol compared to tamoxifen used alone. Cancer Res. Aug. 1982;42(8 Suppl):3458s-60s. Not eligible target population. [pmid: 7044528].
2092 Prayaga AK, Loya AC, Gottimukkala SR, et al. Cytologic features of primary malignant tumors of skin and adnexae. Acta Cytol. Nov–Dec. 2008;52(6):702-9. Not eligible target population. [pmid: 19068675].
2093 Pretorius ES, Hruban RH, Fishman EK. Recurrent fibromatosis in a patient with breast carcinoma. Computed tomography findings with magnetic resonance imaging and pathologic correlation. Invest Radiol. Jun. 1995;30(6):381-3. Case Reports. [pmid: 7490191].
2094 Price P, Sinnett HD, Gusterson B, et al. Duct carcinoma in situ: predictors of local recurrence and progression in patients treated by surgery alone. Br J Cancer. Jun. 1990;61(6):869-72. Not eligible level of evidence. [pmid: 2164835].
2095 Prinjha S, Evans J, McPherson A. Women’s information needs about ductal carcinoma in situ before mammographic screening and after diagnosis: a qualitative study. J Med Screen. 2006;13(3):110-4. Not eligible outcomes. [pmid: 17007650].
2096 Pritt B, Ashikaga T, Oppenheimer RG, et al. Influence of breast cancer histology on the relationship between ultrasound and pathology tumor size measurements. Mod Pathol. Aug. 2004;17(8):905-10. Not eligible outcomes. [pmid: 15105809].
2097 Pritt B, Pang Y, Kellogg M, et al. Diagnostic value of nipple cytology: study of 466 cases. Cancer. Aug. 25. 2004;102(4):233-8. Not eligible outcomes. [pmid: 15368315].
2098 Pronzato P, Bertelli G, Rosso M. A randomized trial on tamoxifen continuation during second-line hormone therapy in breast cancer. Ann N Y Acad Sci. Nov. 30. 357. 1993:698-61. Not eligible target population.
2099 Pronzato P, Rubagotti A, Amoroso D, et al. Second-line hormonotherapy for breast cancer. Uselessness of first-line continuation. Am J Clin Oncol. Dec. 1993;16(6):522-5. Not eligible target population. [pmid: 8256770].
2100 Proudfoot RW, Mattingly SS, Stelling CB, et al. Nonpalpable breast lesions: wire localization and excisional biopsy. Am Surg. Mar. 1986;52(3):117-22. Not eligible outcomes. [pmid: 3006562].
2101 Provenzano E, Hopper JL, Giles GG, et al. Histological markers that predict clinical recurrence in ductal carcinoma in situ of the breast: an Australian population-based study. Pathology. Jun. 2004;36(3):221-9. Not eligible level of evidence. [pmid: 15203725].
2102 Pruthi S, Boughey JC, Brandt KR, et al. A multidisciplinary approach to the management of breast cancer, part 2: therapeutic considerations. Mayo Clin Proc. Sep. 2007;82(9):1131-40. No primary data. [pmid: 17803883].
2103 Psarianos T, Kench JG, Ung OA, et al. Breast carcinoma in a fibroadenoma: diagnosis by fine needle aspiration cytology. Pathology. Nov. 1998;30(4):419-21. Case Reports. [pmid: 9839320].
2104 Pucci-Minafra I, Minafra S, Faccini AM, et al. An ultrastructural evaluation of cell heterogeneity in invasive ductal carcinomas of the human breast. I. An in vivo study. J Submicrosc Cytol Pathol. Jul. 1989;21(3):475-88. Not eligible outcomes. [pmid: 2551481].
2105 Puckett C. Current concepts in the treatment of early stage breast cancer. Del Med J. May. 1992;64(5):313-9. Case Reports. [pmid: 1319354].
2106 Puyau FA. Needle localization of occult breast cancer for surgical biopsy. J La State Med Soc. Aug. 1988;140(8):33-6. Not eligible outcomes. [pmid: 2844989].
2107 Quan ML, Hodgson N, Lovrics P, et al. National adoption of sentinel node biopsy for breast cancer: lessons learned from the Canadian experience. Breast Journal. Sep–Oct. 2008;14(5):421-7. Not eligible target population. [pmid: 18657140].
2108 Queisser W, Doss A, Wander HE, et al. Phase II study of vinorelbine by oral route (in a hard gelatine capsule) for metastatic breast cancer patients. A trial of the phase I/II study group of the Association for Medical Oncology of the German Cancer Society. Onkologie. Feb. 1991;14(1):35-9. Not eligible target population. [pmid: 1647510].
2109 Quenneville LA, Phillips KA, Ozcelik H, et al. HER-2/neu status and tumor morphology of invasive breast carcinomas in Ashkenazi women with known BRCA1 mutation status in the Ontario Familial Breast Cancer Registry. Cancer. Nov. 15. 2002;95(10):2068-75. Not eligible target population. [pmid: 12412159].
2110 Querzoli P, Albonico G, Ferretti S, et al. Quantitative immunoprofiles of breast cancer performed by image analysis. Anal Quant Cytol Histol. Apr. 1999;21(2):151-60. Not eligible outcomes. [pmid: 10560485].
2111 Quinn CM, Ostrowski JL. Cytological and architectural heterogeneity in ductal carcinoma in situ of the breast. J Clin Pathol. Jul. 1997;50(7):596-9. Not eligible outcomes. [pmid: 9306942].
2112 Quinn CM, Ostrowski JL, Harkins L, et al. Loss of bcl-2 expression in ductal carcinoma in situ of the breast relates to poor histological differentiation and to expression of p53 and c-erbB-2 proteins. Histopathology. Dec. 1998;33(6):531-6. Not eligible outcomes. [pmid: 9870147].
2113 Quinn CM, Ostrowski JL, Parkin GJ, et al. Ductal carcinoma in situ of the breast: the clinical significance of histological classification. Histopathology. Feb. 1997;30(2):113-9. Not eligible target population. [pmid: 9067733].
2114 Quinn MJ, Cooper N, Rachet B, et al. Survival from cancer of the breast in women in England and Wales up to 2001. Br J Cancer. Sep. 23. 2008;99(Suppl 1):S53-5. Not eligible outcomes. [pmid: 18813260].
2115 Rabinovitch RA, Solin LJ, Shank BM, et al. Ductal carcinoma in situ and microinvasive disease. American College of Radiology. ACR Appropriateness Criteria. Radiology. Jun. 2000;215(Suppl):1137-52. Guidelines. [pmid: 11037538].
2116 Raccurt M, Tam SP, Lau P, et al. Suppressor of cytokine signalling gene expression is elevated in breast carcinoma. Br J Cancer. Aug. 4. 2003;89(3):524-32. Not eligible outcomes. [pmid: 12888825].
2117 Radford DM, Cromack DT, Troop BR, et al. Pathology and treatment of impalpable breast lesions. Am J Surg. Nov. 1992;164(5):427-31. discussion 31-2. Not eligible outcomes. [pmid: 1332522].
2118 Radford DM, Fair K, Thompson AM, et al. Allelic loss on a chromosome 17 in ductal carcinoma in situ of the breast. Cancer Res. Jul. 1. 1993;53(13):2947-9. Not eligible outcomes. [pmid: 8391383].
2119 Radhakrishnan VV, Aikat BK. Elastosis in breast carcinoma. Indian J Cancer. Dec. 1977;14(4):307-12. Not eligible outcomes. [pmid: 206511].
2120 Radke I, Gotte M, Kersting C, et al. Expression and prognostic impact of the protein tyrosine phosphatases PRL-1, PRL-2, and PRL-3 in breast cancer. Br J Cancer. Aug. 7. 2006;95(3):347-54. Not eligible outcomes. [pmid: 16832410].
2121 Rae V, Gould E, Ibe MJ, et al. Coexistent pemphigus vulgaris and Paget’s disease of the nipple. An immunohistochemical study. J Am Acad Dermatol. Jan. 1987;16(1 Pt 2):235-7. Not eligible target population. [pmid: 3029190].
2122 Rahusen FD, Taets van Amerongen AH, van Diest PJ, et al. Ultrasound-guided lumpectomy of nonpalpable breast cancers: A feasibility study looking at the accuracy of obtained margins. J Surg Oncol. Oct. 1999;72(2):72-6. Not eligible outcomes. [pmid: 10518102].
2123 Rajesh L, Dey P, Joshi K. Automated image morphometry of lobular breast carcinoma. Anal Quant Cytol Histol. Apr. 2002;24(2):81-4. Not eligible outcomes. [pmid: 12026054].
2124 Rajhans R, Nair S, Holden AH, et al. Oncogenic potential of the nuclear receptor coregulator proline-, glutamic acid-, leucine-rich protein 1/modulator of the nongenomic actions of the estrogen receptor. Cancer Res. Jun. 1. 2007;67(11):5505-12. Not eligible outcomes. [pmid: 17545633].
2125 Raju U, Vertes D. Breast papillomas with atypical ductal hyperplasia: a clinicopathologic study. Hum Pathol. Nov. 1996;27(11):1231-8. Not eligible outcomes. [pmid: 8912836].
2126 Raju U, Zarbo RJ, Kubus J, et al. The histologic spectrum of apocrine breast proliferations: a comparative study of morphology and DNA content by image analysis. Hum Pathol. Feb. 1993;24(2):173-81. Not eligible outcomes. [pmid: 8381766].
2127 Rakha EA, El-Sayed ME, Reed J, et al. Screen-detected breast lesions with malignant needle core biopsy diagnoses and no malignancy identified in subsequent surgical excision specimens (potential false-positive diagnosis). Eur J Cancer. 2009. Jan. 2. Not eligible outcomes.
2128 Rakovitch E, Franssen E, Kim J, et al. A comparison of risk perception and psychological morbidity in women with ductal carcinoma in situ and early invasive breast cancer. Breast Cancer Res Treat. Feb. 2003;77(3):285-93. Not eligible outcomes. [pmid: 12602928].
2129 Rakovitch E, Mihai A, Pignol JP, et al. Is expert breast pathology assessment necessary for the management of ductal carcinoma in situ. Breast Cancer Res Treat. Oct. 2004;87(3):265-72. Not eligible outcomes. [pmid: 15528969].
2130 Ramsaroop R, Greenberg D, Tracey N, et al. Mucocele-like lesions of the breast: an audit of 2 years at BreastScreen Auckland (New Zealand). Breast J. Sep–Oct. 2005;11(5):321-5. Not eligible outcomes. [pmid: 16174152].
2131 Ramstad T, Lawnicki L, Vetto J, et al. Immunohistochemical analysis of primary breast tumors and tumor-draining lymph nodes by means of the T-cell costimulatory molecule OX-40. Am J Surg. May. 2000;179(5):400-6. Not eligible outcomes. [pmid: 10930490].
2132 Rand RW, Rand RP, Eggerding F, et al. Cryolumpectomy for carcinoma of the breast. Surg Gynecol Obstet. Nov. 1987;165(5):392-6. Not eligible target population. [pmid: 2823400].
2133 Ranger GS, Jewell A, Thomas V, et al. Elevated expression of cyclooxygenase-2 in breast cancer and ductal carcinoma in situ has no correlation with established prognostic markers. J Surg Oncol. Nov. 1. 2004;88(2):100-3. Not eligible outcomes. [pmid: 15499599].
2134 Ranieri E, D’Andrea MR, D’Alessio A, et al. The integration of diagnostic tests and the role of outpatient surgery in the management of breast disease. Int Surg. Apr–Jun. 1995;80(2):181-4. Not eligible outcomes. [pmid: 8530240].
2135 Ranieri E, Virno F, D’Andrea MR, et al. The role of cytology in differentiation of breast lesions. Anticancer Res. Mar–Apr. 1995;15(2):607-11. Not eligible outcomes. [pmid: 7763045].
2136 Rao A, Parker S, Ratzer E, et al. Atypical ductal hyperplasia of the breast diagnosed by 11-gauge directional vacuum-assisted biopsy. Am J Surg. Dec. 2002;184(6):534-7. discussion 7. Not eligible outcomes. [pmid: 12488158].
2137 Rao AV, Mohammed WA, Ragoonanan C, et al. Evaluation of oestrogen and progesterone receptors, and c-erbB-2 in carcinoma of the breast in Trinidadian women. West Indian Med J. Mar. 2002;51(1):4-9. Not eligible outcomes. [pmid: 12089875].
2138 Rao RS, Taylor J, Palmer J, et al. Breast cancer pseudometastasis in a sentinel lymph node with cytokeratin-positive debris. Breast J. Mar–Apr. 2005;11(2):134-7. Case Reports. [pmid: 15730460].
2139 Rao S, Brien HW, Strassle P. Cauda equina compression associated with breast cancer. A case study in differential diagnosis. Clin Orthop Relat Res. May. 1991;(266):80-4. Case Reports.
2140 Rashid-Kolvear F, Pintilie M, Done SJ. Telomere length on chromosome 17q shortens more than global telomere length in the development of breast cancer. Neoplasia. Apr. 2007;9(4):265-70. Not eligible outcomes. [pmid: 17460770].
2141 Rashtian A, Iganej S, Amy Liu IL, et al. Close or positive margins after mastectomy for DCIS: pattern of relapse and potential indications for radiotherapy. Int J Radiat Oncol Biol Phys. Nov. 15. 2008;72(4):1016-20. Not eligible level of evidence. [pmid: 18954711].
2142 Ratanawichitrasin A, Rybicki LA, Steiger E, et al. Predicting the likelihood of residual disease in women treated for ductal carcinoma in situ. J Am Coll Surg. Jan. 1999;188(1):17-21. Not eligible outcomes. [pmid: 9915237].
2143 Rauta J, Alarmo EL, Kauraniemi P, et al. The serine-threonine protein phosphatase PPM1D is frequently activated through amplification in aggressive primary breast tumours. Breast Cancer Res Treat. Feb. 2006;95(3):257-63. Not eligible outcomes. [pmid: 16254685].
2144 Ray GR, Adelson J, Hayhurst E, et al. Ductal carcinoma in situ of the breast: results of treatment by conservative surgery and definitive irradiation. Int J Radiat Oncol Biol Phys. Jan. 1. 1994;28(1):105-11. Not eligible level of evidence. [pmid: 8270430].
2145 Raza S, Vallejo M, Chikarmane SA, et al. Pure ductal carcinoma in situ: a range of MRI features. AJR Am J Roentgenol. Sep. 2008;191(3):689-99. Not eligible level of evidence. [pmid: 18716095].
2146 Recht A. Treatment of in situ ductal breast cancer. Front Radiat Ther Oncol. 1993;27:52-61. Secondary data analysis. [pmid: 8389309].
2147 Redfern AB, Hoopes JE. Subcutaneous mastectomy: a plea for conservatism. Plast Reconstr Surg. Nov. 1978;62(5):706-7. Not eligible target population. [pmid: 715021].
2148 Redlich PN, Purdy AC, Shidham VB, et al. Feasibility of breast duct lavage performed by a physician extender. Surgery. Nov. 2004;136(5):1077-80. discussion 80-2. Not eligible outcomes. [pmid: 15523404].
2149 Redondo M, Villar E, Torres-Munoz J, et al. Overexpression of clusterin in human breast carcinoma. Am J Pathol. Aug. 2000;157(2):393-9. Not eligible outcomes. [pmid: 10934144].
2150 Reena RM, Mastura M, Siti-Aishah MA, et al. Minichromosome maintenance protein 2 is a reliable proliferative marker in breast carcinoma. Ann Diagn Pathol. Oct. 2008;12(5):340-3. Not eligible target population. [pmid: 18774496].
2151 Rees TD, Coburn R. Breast reduction: is it an aid to cancer detection. Br J Plast Surg. Apr. 1972;25(2):144-6. Case Reports. [pmid: 4336802].
2152 Reeves MJ, Osuch JR, Pathak DR. Development of a clinical decision rule for triage of women with palpable breast masses. J Clin Epidemiol. Jul. 2003;56(7):636-45. Not eligible outcomes. [pmid: 12921932].
2153 Regele S, Kohlberger P, Vogl FD, et al. Serum p53 autoantibodies in patients with minimal lesions of ductal carcinoma in situ of the breast. Br J Cancer. Oct. 1999;81(4):702-4. Not eligible outcomes. [pmid: 10574259].
2154 Regolo L, Ballardini B, Gallarotti E, et al. Nipple sparing mastectomy: an innovative skin incision for an alternative approach. Breast. Feb. 2008;17(1):8-11. Not eligible exposure. [pmid: 17870535].
2155 Rehman S, Crow J, Revell PA. Bax protein expression in DCIS of the breast in relation to invasive ductal carcinoma and other molecular markers. Pathol Oncol Res. 2000;6(4):256-63. Not eligible outcomes. [pmid: 11173657].
2156 Reiff DB, Cooke J, Griffin M, et al. Ductal carcinoma in situ presenting as a stellate lesion on mammography. Clin Radiol. Jun. 1994;49(6):396-9. Not eligible outcomes. [pmid: 8045063].
2157 Reinbach D, McGregor JR, O’Dwyer PJ, et al. Synchronous male breast carcinoma and soft tissue sarcoma occurring within a cancer family. Eur J Surg Oncol. Dec. 1992;18(6):624-6. Not eligible target population. [pmid: 1335887].
2158 Reinholz MM, Iturria SJ, Ingle JN, et al. Differential gene expression of TGF-beta family members and osteopontin in breast tumor tissue: analysis by real-time quantitative PCR. Breast Cancer Res Treat. Jun. 2002;74(3):255-69. Not eligible target population. [pmid: 12206515].
2159 Reinholz MM, Nibbe A, Jonart LM, et al. Evaluation of a panel of tumor markers for molecular detection of circulating cancer cells in women with suspected breast cancer. Clin Cancer Res. May. 15. 2005;11(10):3722-32. Not eligible outcomes. [pmid: 15897569].
2160 Reis-Filho JS, Fulford LG, Lakhani SR, et al. Pathologic quiz case: a 62-year-old woman with a 4.5-cm nodule in the right breast. Lipid-rich breast carcinoma. Arch Pathol Lab Med. Sep. 2003;127(9):e396-8. Case Reports. [pmid: 12951994].
2161 Reis-Filho JS, Milanezi F, Amendoeira I, et al. p63 Staining of myoepithelial cells in breast fine needle aspirates: a study of its role in differentiating in situ from invasive ductal carcinomas of the breast. J Clin Pathol. Dec. 2002;55(12):936-9. Not eligible outcomes. [pmid: 12461063].
2162 Reis-Filho JS, Milanezi F, Amendoeira I, et al. Distribution of p63, a novel myoepithelial marker, in fine-needle aspiration biopsies of the breast: an analysis of 82 samples. Cancer. Jun. 25. 2003;99(3):172-9. Not eligible outcomes. [pmid: 12811858].
2163 Reis-Filho JS, Steele D, Di Palma S, et al. Distribution and significance of nerve growth factor receptor (NGFR/p75NTR) in normal, benign and malignant breast tissue. Mod Pathol. Feb. 2006;19(2):307-19. Not eligible outcomes. [pmid: 16424897].
2164 Reitsamer R, Peintinger F, Kopp M, et al. Local recurrence rates in breast cancer patients treated with intraoperative electron-boost radiotherapy versus postoperative external-beam electron-boost irradiation. A sequential intervention study. Strahlenther Onkol. Jan. 2004;180(1):38-44. Not eligible target population. [pmid: 14704843].
2165 Renshaw AA. Improved reporting methods for atypia and atypical ductal hyperplasia in breast core needle biopsy specimens. Potential for interlaboratory comparisons. Am J Clin Pathol. Jul. 2001;116(1):87-91. Not eligible outcomes. [pmid: 11447757].
2166 Renshaw AA. Adequate histologic sampling of breast core needle biopsies. Arch Pathol Lab Med. Aug. 2001;125(8):1055-7. Not eligible outcomes. [pmid: 11473457].
2167 Renshaw AA. Predicting invasion in the excision specimen from breast core needle biopsy specimens with only ductal carcinoma in situ. Arch Pathol Lab Med. Jan. 2002;126(1):39-41. Not eligible outcomes. [pmid: 11800645].
2168 Renshaw AA. Can mucinous lesions of the breast be reliably diagnosed by core needle biopsy. Am J Clin Pathol. Jul. 2002;118(1):82-4. Not eligible outcomes. [pmid: 12109860].
2169 Renshaw AA. Minimal (< or =0.1 cm) invasive carcinoma in breast core needle biopsies. Incidence, sampling, associated findings, and follow-up. Arch Pathol Lab Med. Sep. 2004;128(9):996-9. Not eligible outcomes. [pmid: 15335264].
2170 Renshaw AA, Cartagena N, Derhagopian RP, et al. Lobular neoplasia in breast core needle biopsy specimens is not associated with an increased risk of ductal carcinoma in situ or invasive carcinoma. Am J Clin Pathol. May. 2002;117(5):797-9. Not eligible target population. [pmid: 12090431].
2171 Renshaw AA, Cartagena N, Schenkman RH, et al. Atypical ductal hyperplasia in breast core needle biopsies. Correlation of size of the lesion, complete removal of the lesion, and the incidence of carcinoma in follow-up biopsies. Am J Clin Pathol. Jul. 2001;116(1):92-6. Not eligible outcomes. [pmid: 11447758].
2172 Renshaw AA, Derhagopian RP, Martinez P, et al. Lobular neoplasia in breast core needle biopsy specimens is associated with a low risk of ductal carcinoma in situ or invasive carcinoma on subsequent excision. Am J Clin Pathol. Aug. 2006;126(2):310-3. Not eligible exposure. [pmid: 16891208].
2173 Renshaw AA, Derhagopian RP, Tizol-Blanco DM, et al. Papillomas and atypical papillomas in breast core needle biopsy specimens: risk of carcinoma in subsequent excision. Am J Clin Pathol. Aug. 2004;122(2):217-21. Not eligible target population. [pmid: 15323138].
2174 Resetkova E, Albarracin C, Sneige N. Collagenous spherulosis of breast: morphologic study of 59 cases and review of the literature. Am J Surg Pathol. Jan. 2006;30(1):20-7. Not eligible outcomes. [pmid: 16330938].
2175 Reynolds JV, Sweeney JP, Nolan N, et al. Management of ductal carcinoma in situ of the breast. Ir J Med Sci. Feb. 1993;162(2):45-8. Not eligible level of evidence. [pmid: 8383101].
2176 Ribeiro GG, Magee B, Swindell R, et al. The Christie Hospital breast conservation trial: an update at 8 years from inception. Clin Oncol (R Coll Radiol). 1993;5(5):278-83. Not eligible target population. [pmid: 8305334].
2177 Ribeiro-Silva A, Oliveira da Costa JP. Osteopontin expression according to molecular profile of invasive breast cancer: a clinicopathological and immunohistochemical study. Int J Biol Markers. Jul–Sep. 2008;23(3):154-60. Not eligible target population. [pmid: 18949741].
2178 Ribeiro-Silva A, Zamzelli Ramalho LN, Garcia SB, et al. Is p63 reliable in detecting microinvasion in ductal carcinoma in situ of the breast. Pathol Oncol Res. 2003;9(1):20-3. Not eligible outcomes. [pmid: 12704442].
2179 Rice AJ, Steward MA, Quinn CM. Thrombospondin 1 protein expression relates to good prognostic indices in ductal carcinoma in situ of the breast. J Clin Pathol. Dec. 2002;55(12):921-5. Not eligible outcomes. [pmid: 12461058].
2180 Rice DC, Morris SM, Sarr MG, et al. Intraoperative topical tetracycline sclerotherapy following mastectomy: a prospective, randomized trial. J Surg Oncol. Apr. 2000;73(4):224-7. Not eligible outcomes. [pmid: 10797336].
2181 Richter-Ehrenstein C, Mueller S, Noske A, et al. Diagnostic Accuracy and Prognostic Value of Core Biopsy in the Management of Breast Cancer: A Series of 542 Patients. Int J Surg Pathol. 2008. Nov. 24. Not eligible outcomes.
2182 Rickard MT. Ultrasound of malignant breast microcalcifications: role in evaluation and guided procedures. Australas Radiol. Feb. 1996;40(1):26-31. Case Reports. [pmid: 8838884].
2183 Rickard MT, Selopranoto US. Paget’s disease of the breast: what the radiologist may expect to find. Australas Radiol. Feb. 1995;39(1):27-30. Not eligible target population. [pmid: 7695525].
2184 Ridolfi RL, Jamehdor MR, Arber JM. HER-2/neu testing in breast carcinoma: a combined immunohistochemical and fluorescence in situ hybridization approach. Mod Pathol. Aug. 2000;13(8):866-73. Not eligible outcomes. [pmid: 10955453].
2185 Rieche K, Wolff G. Comparison of testosterone decanoate, drostanolone and testololactone in disseminated breast cancer--a randomized clinical study. Arch Geschwulstforsch. 1975;45(5):485-8. Not eligible target population. [pmid: 1243528].
2186 Riley LB, Lange MK, Browne RJ, et al. Analysis of cathepsin D in human breast cancer: usefulness of the processed 31 kDa active form of the enzyme as a prognostic indicator in node-negative and node-positive patients. Breast Cancer Res Treat. Mar. 2000;60(2):173-9. Not eligible outcomes. [pmid: 10845280].
2187 Riman T, Dickman PW, Nilsson S, et al. Hormone replacement therapy and the risk of invasive epithelial ovarian cancer in Swedish women. J Natl Cancer Inst. Apr. 3. 2002;94(7):497-504. not eligible outcomes. [pmid: 11929950].
2188 Ringberg A, Andersson I, Aspegren K, et al. Breast carcinoma in situ in 167 women--incidence, mode of presentation, therapy and follow-up. Eur J Surg Oncol. Oct. 1991;17(5):466-76. Not eligible outcomes. [pmid: 1657650].
2189 Rissanen TJ, Makarainen HP, Apaja-Sarkkinen MA, et al. Mammography and ultrasound in the diagnosis of contralateral breast cancer. Acta Radiol. Jul. 1995;36(4):358-66. Not eligible outcomes. [pmid: 7619612].
2190 Rizzo M, Lund MJ, Oprea G, et al. Surgical follow-up and clinical presentation of 142 breast papillary lesions diagnosed by ultrasound-guided core-needle biopsy. Ann Surg Oncol. Apr. 2008;15(4):1040-7. Not eligible outcomes. [pmid: 18204989].
2191 Ro JY, Ngadiman S, Sahin A, et al. Intraluminal crystalloids in breast carcinoma. Immunohistochemical, ultrastructural, and energy-dispersive x-ray element analysis in four cases. Arch Pathol Lab Med. Jun. 1997;121(6):593-8. Not eligible outcomes. [pmid: 9199624].
2192 Ro JY, Sneige N, Sahin AA, et al. Mucocelelike tumor of the breast associated with atypical ductal hyperplasia or mucinous carcinoma. A clinicopathologic study of seven cases. Arch Pathol Lab Med. Feb. 1991;115(2):137-40. Not eligible target population. [pmid: 1847035].
2193 Robanus-Maandag EC, Bosch CA, Kristel PM, et al. Association of C-MYC amplification with progression from the in situ to the invasive stage in C-MYC-amplified breast carcinomas. J Pathol. Sep. 2003;201(1):75-82. Not eligible outcomes. [pmid: 12950019].
2194 Robertson JF, Erikstein B, Osborne KC, et al. Pharmacokinetic profile of intramuscular fulvestrant in advanced breast cancer. Clin Pharmacokinet. 2004;43(8):529-38. Not eligible target population. [pmid: 15170367].
2195 Robertson JF, Osborne CK, Howell A, et al. Fulvestrant versus anastrozole for the treatment of advanced breast carcinoma in postmenopausal women: a prospective combined analysis of two multicenter trials. Cancer. Jul. 15. 2003;98(2):229-38. Not eligible target population. [pmid: 12872340].
2196 Robertson JM, Clarke DH, Pevzner MM, et al. Breast conservation therapy. Severe breast fibrosis after radiation therapy in patients with collagen vascular disease. Cancer. Aug. 1. 1991;68(3):502-8. Case Reports. [pmid: 1648431].
2197 Robinson D, Holmberg L, Moller H. The occurrence of invasive cancers following a diagnosis of breast carcinoma in situ. British journal of cancer. Aug. 19. 2008;99(4):611-5. Not eligible outcomes. [pmid: 18665169].
2198 Robustelli della Cuna G, Pannuti F, Martoni A, et al. Aminoglutethimide in advanced breast cancer: prospective, randomized comparison of two dose levels. Italian Cooperative Group. Anticancer Res. Nov–Dec. 1993;13(6B):2367-71. Not eligible target population. [pmid: 8135469].
2199 Rodd CD, Velchuru VR, Holly-Archer F, et al. Randomized clinical trial comparing two mastectomy techniques. World J Surg. Jun. 2007;31(6):1164-8. Not eligible outcomes. [pmid: 17417709].
2200 Rodrigues NA, Dillon D, Carter D, et al. Differences in the pathologic and molecular features of intraductal breast carcinoma between younger and older women. Cancer. Mar. 15. 2003;97(6):1393-403. Not eligible outcomes. [pmid: 12627502].
2201 Rodriguez N, Diaz LK, Wiley EL. Predictors of residual disease in repeat excisions for lumpectomies with margins less than 0.1 cm. Clin Breast Cancer. Jun. 2005;6(2):169-72. Not eligible outcomes. [pmid: 16001996].
2202 Rody A, Diallo R, Poremba C, et al. Estrogen receptor alpha and beta, progesterone receptor, pS2 and HER-2/neu expression delineate different subgroups in ductal carcinoma in situ of the breast. Oncol Rep. Oct. 2004;12(4):695-9. Not eligible outcomes. [pmid: 15375487].
2203 Rody A, Diallo R, Poremba C, et al. Androgen receptor expression in ductal carcinoma in situ of the breast: not a helpful marker for classification such as estrogen receptor alpha and progesterone receptor. Appl Immunohistochem Mol Morphol. Mar. 2005;13(1):25-9. Not eligible outcomes. [pmid: 15722790].
2204 Roger P, Sahla ME, Makela S, et al. Decreased expression of estrogen receptor beta protein in proliferative preinvasive mammary tumors. Cancer Res. Mar. 15. 2001;61(6):2537-41. Not eligible outcomes. [pmid: 11289127].
2205 Rogers S, Docherty SE, Slavin JL, et al. Differential expression of GLUT12 in breast cancer and normal breast tissue. Cancer Lett. Apr. 25. 2003;193(2):225-33. Not eligible outcomes. [pmid: 12706881].
2206 Rohan TE, Hartwick W, Miller AB, et al. Immunohistochemical detection of c-erbB-2 and p53 in benign breast disease and breast cancer risk. J Natl Cancer Inst. Sep. 2. 1998;90(17):1262-9. Not eligible outcomes. [pmid: 9731732].
2207 Ron IG, Inbar MJ, Barak Y, et al. Organic delusional syndrome associated with tamoxifen treatment. Cancer. Mar. 15. 1992;69(6):1415-7. Case Reports. [pmid: 1311624].
2208 Ronnerdag M, Odlind V. Health effects of long-term use of the intrauterine levonorgestrel-releasing system. A follow-up study over 12 years of continuous use. Acta Obstet Gynecol Scand. Sep. 1999;78(8):716-21. Not eligible outcomes. [pmid: 10468065].
2209 Roorda AK, Hansen JP, Rider JA, et al. Ectopic breast cancer: special treatment considerations in the postmenopausal patient. Breast J. Sep–Oct. 2002;8(5):286-9. Case Reports. [pmid: 12199756].
2210 Rose C, Kamby C, Mouridsen HT, et al. Combined endocrine treatment of elderly postmenopausal patients with metastatic breast cancer. A randomized trial of tamoxifen vs. tamoxifen + aminoglutethimide and hydrocortisone and tamoxifen + fluoxymesterone in women above 65 years of age. Breast Cancer Res Treat. May. 2000;61(2):103-10. Not eligible target population. [pmid: 10942095].
2211 Rose C, Kamby C, Mouridsen HT, et al. Combined endocrine treatment of postmenopausal patients with advanced breast cancer. A randomized trial of tamoxifen vs. tamoxifen plus aminoglutethimide and hydrocortisone. Breast Cancer Res Treat. 1986;7(Supp):S45-50. Not eligible target population. [pmid: 3527306].
2212 Rose C, Vtoraya O, Pluzanska A, et al. An open randomised trial of second-line endocrine therapy in advanced breast cancer. comparison of the aromatase inhibitors letrozole and anastrozole. Eur J Cancer. Nov. 2003;39(16):2318-27. Not eligible target population. [pmid: 14556923].
2213 Rosen HR, Stierer M, Gottlicher J, et al. Determination of placental ferritin-positive peripheral lymphocytes in early stages of breast cancer. Am J Surg. Feb. 1993;165(2):213-7. Not eligible outcomes. [pmid: 8427398].
2214 Rosen PP, Braun DW Jr, Kinne DE. The clinical significance of pre-invasive breast carcinoma. Cancer. Aug. 15. 1980;46(4 Suppl):919-25. Not eligible target population. [pmid: 7397668].
2215 Rosen PP, Caicco JA. Florid papillomatosis of the nipple. A study of 51 patients, including nine with mammary carcinoma. Am J Surg Pathol. Feb. 1986;10(2):87-101. Not eligible outcomes. [pmid: 3006526].
2216 Rosen PP, Jozefczyk MA, Boram LH. Vascular tumors of the breast. IV. The venous hemangioma. Am J Surg Pathol. Sep. 1985;9(9):659-65. Case Reports. [pmid: 4051098].
2217 Rosen PP, Kimmel M. Juvenile papillomatosis of the breast. A follow-up study of 41 patients having biopsies before 1979. Am J Clin Pathol. May. 1990;93(5):599-603. Not eligible target population. [pmid: 2158224].
2218 Rosen PP, Tench W. Lobules in the nipple. Frequency and significance for breast cancer treatment. Pathol Annu. 1985;20(Pt 2):317-22. Not eligible target population. [pmid: 2989757].
2219 Rosenblatt R, Fineberg SA, Sparano JA, et al. Stereotactic core needle biopsy of multiple sites in the breast: efficacy and effect on patient care. Radiology. Oct. 1996;201(1):67-70. Not eligible outcomes. [pmid: 8816522].
2220 Rosenfeld I, Tartter PI, Gajdos C, et al. The significance of malignancies incidental to microcalcifications in breast spot localization biopsy specimens. Am J Surg. Jul. 2001;182(1):1-5. Not eligible outcomes. [pmid: 11532405].
2221 Roses DF, Harris MN, Gorstein F, et al. Biopsy for microcalcification detected by mammography. Surgery. Mar. 1980;87(3):248-52. Not eligible outcomes. [pmid: 6244682].
2222 Rosner D, Lane WW. Should all patients with node-negative breast cancer receive adjuvant therapy? Identifying additional subsets of low-risk patients who are highly curable by surgery alone. Cancer. Oct. 1. 1991;68(7):1482-94. Not eligible target population. [pmid: 1893347].
2223 Rosner D, Lane WW. Predicting recurrence in axillary-node negative breast cancer patients. Breast Cancer Res Treat. 1993;25(2):127-39. Not eligible target population. [pmid: 8347845].
2224 Rosner D, Lane WW, Penetrante R. Ductal carcinoma in situ with microinvasion. A curable entity using surgery alone without need for adjuvant therapy. Cancer. Mar. 15. 1991;67(6):1498-503. Not eligible level of evidence. [pmid: 1848153].
2225 Rosselli Del Turco M, Ciatto S, Bravetti P, et al. The significance of mammographic calcifications in early breast cancer detection. Radiol Med (Torino). Jan–Feb. 1986;72(1-2):7-12. Not eligible outcomes. [pmid: 3008222].
2226 Rossi E, Morabito A, De Maio E, et al. Endocrine effects of adjuvant letrozole + triptorelin compared with tamoxifen + triptorelin in premenopausal patients with early breast cancer. J Clin Oncol. Jan. 10. 2008;26(2):264-70. Not eligible target population. [pmid: 18086795].
2227 Rostom YA, Chapet O, Russo SM, et al. Intra-operative electron radiotherapy as a conservative treatment for infiltrating bladder cancer. Eur J Cancer. Sep. 2000;36(14):1781-7. Not eligible target population. [pmid: 10974626].
2228 Rouanet P, Linares-Cruz G, Dravet F, et al. Neoadjuvant percutaneous 4-hydroxytamoxifen decreases breast tumoral cell proliferation: a prospective controlled randomized study comparing three doses of 4-hydroxytamoxifen gel to oral tamoxifen. J Clin Oncol. May. 1. 2005;23(13):2980-7. Not eligible outcomes. [pmid: 15860853].
2229 Roubidoux MA, Helvie MA, Lai NE, et al. Bilateral breast cancer: early detection with mammography. Radiology. Aug. 1995;196(2):427-31. Not eligible outcomes. [pmid: 7617856].
2230 Roubidoux MA, Helvie MA, Wilson TE, et al. Women with breast cancer: histologic findings in the contralateral breast. Radiology. Jun. 1997;203(3):691-4. Not eligible exposure. [pmid: 9169690].
2231 Roubidoux MA, Sabel MS, Bailey JE, et al. Small (< 2.0-cm) breast cancers: mammographic and US findings at US-guided cryoablation--initial experience. Radiology. Dec. 2004;233(3):857-67. Not eligible outcomes. [pmid: 15567802].
2232 Roukema JA, Leenen LP, Kuizinga MC, et al. Angiosarcoma of the irradiated breast: a new problem after breast conserving therapy. Neth J Surg. Aug. 1991;43(4):114-6. Case Reports. [pmid: 1658688].
2233 Rovera F, Dionigi G, Marelli M, et al. Breast cancer diagnosis: The role of stereotactic vacuum-assisted aspiration biopsy. Int J Surg. 2008. Dec. 13. Not eligible outcomes.
2234 Rovera F, Dionigi G, Riva C, et al. Identifying factors contributing to reduced breast tumor size: A longitudinal study. Int J Surg. 2008. Dec. 13. Not eligible outcomes.
2235 Roy SK, Trivedi AH, Bakshi SR, et al. Spontaneous chromosomal instability in breast cancer families. Cancer Genet Cytogenet. Apr. 1. 2000;118(1):52-6. Not eligible outcomes. [pmid: 10731591].
2236 Rubenchik I, Sneige N, Edeiken B, et al. In search of specimen adequacy in fine-needle aspirates of nonpalpable breast lesions. Am J Clin Pathol. Jul. 1997;108(1):13-8. Not eligible outcomes. [pmid: 9208973].
2237 Rubin E, Maddox WA, Mazur MT. Cutaneous angiosarcoma of the breast 7 years after lumpectomy and radiation therapy. Radiology. Jan. 1990;174(1):258-60. Case Reports. [pmid: 2152984].
2238 Rubin E, Visscher DW, Alexander RW, et al. Proliferative disease and atypia in biopsies performed for nonpalpable lesions detected mammographically. Cancer. May. 15. 1988;61(10):2077-82. Not eligible outcomes. [pmid: 3359405].
2239 Rubin P, O’Hanlon D, Browell D, et al. Tumour bed biopsy detects the presence of multifocal disease in patients undergoing breast conservation therapy for primary breast carcinoma. Eur J Surg Oncol. Feb. 1996;22(1):23-6. Not eligible outcomes. [pmid: 8846861].
2240 Rubino A, Fissi S, Secreto G. Bilateral breast cancer in a male patient with hepatocellular carcinoma. A case report. Ann Ital Chir. Mar–Apr. 2008;79(2):117-9. Not eligible target population. [pmid: 18727274].
2241 Rubio IT, Mirza N, Sahin AA, et al. Role of specimen radiography in patients treated with skin-sparing mastectomy for ductal carcinoma in situ of the breast. Ann Surg Oncol. Aug. 2000;7(7):544-8. Not eligible level of evidence. [pmid: 10947024].
2242 Rudas M, Lehnert M, Huynh A, et al. Cyclin D1 expression in breast cancer patients receiving adjuvant tamoxifen-based therapy. Clin Cancer Res. Mar. 15. 2008;14(6):1767-74. Not eligible target population. [pmid: 18347178].
2243 Rudland PS, Leinster SJ, Winstanley J, et al. Immunocytochemical identification of cell types in benign and malignant breast diseases: variations in cell markers accompany the malignant state. J Histochem Cytochem. Apr. 1993;41(4):543-53. Not eligible outcomes. [pmid: 8450194].
2244 Rudnicka L, Stachura J. Correlation between type and grade of ductal carcinoma in situ and concomitant invasive ductal carcinoma of the breast. Pol J Pathol. 2000;51(3):137-43. Not eligible target population. [pmid: 11247396].
2245 Ruhoy SM, Thomas D, Nuovo GJ. Multiple inverted follicular keratoses as a presenting sign of Cowden’s syndrome: case report with human papillomavirus studies. J Am Acad Dermatol. Sep. 2004;51(3):411-5. Case Reports. [pmid: 15337985].
2246 Ruiz de Erenchun F, Vazquez Doval J, Valerdiz S, et al. Inflammatory metastatic carcinoma. A clinical and histopathologic study of three cases. J Dermatol Surg Oncol. Oct. 1991;17(10):784-7. Case Reports. [pmid: 1655850].
2247 Ruiz-Tovar J, Reguero-Callejas ME, Alaez AB, et al. Infiltrating ductal carcinoma and ductal carcinoma in situ associated with mammary hamartoma. Breast J. Jul–Aug. 2006;12(4):368-70. Case Reports. [pmid: 16848850].
2248 Rusnak CH, Pengelly DB, Hosie RT, et al. Preoperative needle localization to detect early breast cancer. Am J Surg. May. 1989;157(5):505-7. Not eligible outcomes. [pmid: 2540666].
2249 Russell CA, Green SJ, O’Sullivan J, et al. Megestrol acetate and aminoglutethimide/hydrocortisone in sequence or in combination as second-line endocrine therapy of estrogen receptor-positive metastatic breast cancer: a Southwest Oncology Group phase III trial. J Clin Oncol. Jul. 1997;15(7):2494-501. Not eligible target population. [pmid: 9215817].
2250 Rutstein LA, Johnson RR, Poller WR, et al. Predictors of residual invasive disease after core needle biopsy diagnosis of ductal carcinoma in situ. Breast J. May–Jun. 2007;13(3):251-7. Not eligible outcomes. [pmid: 17461899].
2251 Ryoo MC, Kagan AR, Wollin M, et al. Prognostic factors for recurrence and cosmesis in 393 patients after radiation therapy for early mammary carcinoma. Radiology. Aug. 1989;172(2):555-9. Not eligible level of evidence. [pmid: 2546175].
2252 Saarela AO, Paloneva TK, Rissanen TJ, et al. Determinants of positive histologic margins and residual tumor after lumpectomy for early breast cancer: a prospective study with special reference to touch preparation cytology. J Surg Oncol. Dec. 1997;66(4):248-53. Not eligible outcomes. [pmid: 9425328].
2253 Sabel MS, Kaufman CS, Whitworth P, et al. Cryoablation of early-stage breast cancer: work-in-progress report of a multi-institutional trial. Ann Surg Oncol. May. 2004;11(5):542-9. Not eligible target population. [pmid: 15123465].
2254 Sabel MS, Rogers K, Griffith K, et al. Residual disease after re-excision lumpectomy for close margins. J Surg Oncol. Feb. 1. 2009;99(2):99-103. Not eligible outcomes. [pmid: 19065638].
2255 Sacchini V, Beal K, Goldberg J, et al. Study of quadrant high-dose intraoperative radiation therapy for early-stage breast cancer. Br J Surg. Sep. 2008;95(9):1105-10. Not eligible target population. [pmid: 18690634].
2256 Sacchini V, Pinotti JA, Barros AC, et al. Nipple-sparing mastectomy for breast cancer and risk reduction: oncologic or technical problem. J Am Coll Surg. Nov. 2006;203(5):704-14. Not eligible target population. [pmid: 17084333].
2257 Saetersdal A, Dorum A, Heimdal K, et al. Inherited predisposition to breast carcinoma. Results of first round examination of 537 women at risk. Anticancer Res. Jul–Aug. 1996;16(4A):1989-92. Not eligible level of evidence. [pmid: 8712731].
2258 Sahin AA, Ro J, Ro JY, et al. Ki-67 immunostaining in node-negative stage I/II breast carcinoma. Significant correlation with prognosis. Cancer. Aug. 1. 1991;68(3):549-57. Not eligible outcomes. [pmid: 1648433].
2259 Sahoo S, Gopal P, Roland L, et al. Cystic hypersecretory carcinoma of the breast with paget disease of the nipple: a diagnostic challenge. Int J Surg Pathol. Apr. 2008;16(2):208-12. Not eligible target population. [pmid: 18417683].
2260 Sahoo S, Green I, Rosen PP. Bilateral paget disease of the nipple associated with lobular carcinoma in situ. Arch Pathol Lab Med. Jan. 2002;126(1):90-2. Case Reports. [pmid: 11800657].
2261 Sahoo S, Recant WM. Triad of columnar cell alteration, lobular carcinoma in situ, and tubular carcinoma of the breast. Breast J. Mar–Apr. 2005;11(2):140-2. Not eligible outcomes. [pmid: 15730461].
2262 Saintot M, Mathieu-Daude H, Astre C, et al. Oxidant-antioxidant status in relation to survival among breast cancer patients. Int J Cancer. Feb. 10. 2002;97(5):574-9. Not eligible level of evidence. [pmid: 11807780].
2263 Sakamoto N, Tozaki M, Higa K, et al. Categorization of non-mass-like breast lesions detected by MRI. Breast Cancer. 2008;15(3):241-6. Not eligible outcomes. [pmid: 18224381].
2264 Sakki S. Angiography of the female breast. Ann Clin Res. 1974;6(Suppl 12):1-47. Not eligible outcomes. [pmid: 4375432].
2265 Salas AP, Helvie MA, Wilkins EG, et al. Is mammography useful in screening for local recurrences in patients with TRAM flap breast reconstruction after mastectomy for multifocal DCIS. Ann Surg Oncol. Jul–Aug. 1998;5(5):456-63. Case Reports. [pmid: 9718177].
2266 Salhab M, Al Sarakbi W, Joseph A, et al. Skin-sparing mastectomy and immediate breast reconstruction: patient satisfaction and clinical outcome. Int J Clin Oncol. Feb. 2006;11(1):51-4. not eligible target population. [pmid: 16508729].
2267 Salvucci O, Bouchard A, Baccarelli A, et al. The role of CXCR4 receptor expression in breast cancer: a large tissue microarray study. Breast Cancer Res Treat. Jun. 2006;97(3):275-83. Not eligible outcomes. [pmid: 16344916].
2268 Samarasinghe D, Frost F, Sterrett G, et al. Cytological diagnosis of Paget’s disease of the nipple by scrape smears: a report of five cases. Diagn Cytopathol. 1993;9(3):291-5. Not eligible target population. [pmid: 8390930].
2269 Samejima N, Yamazaki K. A study on the vascular proliferation in tissues around the tumor in breast cancer. Jpn J Surg. May. 1988;18(3):235-42. Not eligible outcomes. [pmid: 2457129].
2270 Samojlik E, Santen RJ, Worgul TJ. Suppression of residual oestrogen production with aminoglutethimide in women following surgical hypophysectomy or adrenalectomy. Clin Endocrinol (Oxf). Jan. 1984;20(1):43-51. Not eligible target population. [pmid: 6692582].
2271 Samonis G, Margioris AN, Bafaloukos D, et al. Prospective randomized study of aminoglutethimide (AG) versus medroxyprogesterone acetate (MPA) versus AG+MPA in generalized breast cancer. Oncology. Sep–Oct. 1994;51(5):411-5. Not eligible target population. [pmid: 8052481].
2272 Samoszuk M, Leonor L, Espinoza F, et al. Measuring microvascular density in tumors by digital dissection. Anal Quant Cytol Histol. Feb. 2002;24(1):15-22. Not eligible outcomes. [pmid: 11865945].
2273 Samuels JR, Haffty BG, Lee CH, et al. Breast conservation therapy in patients with mammographically undetected breast cancer. Radiology. Nov. 1992;185(2):425-7. not eligible target population. [pmid: 1329142].
2274 Sanchez R, Betancourt L, Sanchez A, et al. Choroidal metastasis as first manifestation of systemic recurrence of breast cancer. Breast J. Sep–Oct. 2008;14(5):498-500. Case Reports. [pmid: 18821936].
2275 Sanchez-Carpintero I, Martinez MI, Mihm MC Jr. Clinical and histopathologic observations of the action of imiquimod in an epithelioid hemangioendothelioma and Paget’s mammary disease. J Am Acad Dermatol. Jul. 2006;55(1):75-9. Case Reports. [pmid: 16781296].
2276 Sanchez-Munoz A, Garcia-Tapiador AM, Martinez-Ortega E, et al. Tumour molecular subtyping according to hormone receptors and HER2 status defines different pathological complete response to neoadjuvant chemotherapy in patients with locally advanced breast cancer. Clin Transl Oncol. Oct. 2008;10(10):646-53. Not eligible target population. [pmid: 18940745].
2277 Sandelin K, Wickman M, Billgren AM. Oncological outcome after immediate breast reconstruction for invasive breast cancer: a long-term study. Breast. Jun. 2004;13(3):210-8. Case Reports. [pmid: 15177424].
2278 Santini D, Pasquinelli G, Alberghini M, et al. Invasive breast carcinoma with granulomatous response and deposition of unusual amyloid. J Clin Pathol. Oct. 1992;45(10):885-8. Case Reports. [pmid: 1331198].
2279 Sapino A, Bongiovanni M, Cassoni P, et al. Expression of CD31 by cells of extensive ductal in situ and invasive carcinomas of the breast. J Pathol. Jun. 2001;194(2):254-61. Not eligible target population. [pmid: 11400156].
2280 Sapino A, Frigerio A, Peterse JL, et al. Mammographically detected in situ lobular carcinomas of the breast. Virchows Arch. May. 2000;436(5):421-30. Not eligible outcomes. [pmid: 10881735].
2281 Saqi A, Mazziotta R, Hamele-Bena D. Columnar cell lesions: fine-needle aspiration biopsy features. Diagn Cytopathol. Dec. 2004;31(6):370-5. Not eligible outcomes. [pmid: 15540173].
2282 Sardanelli F, Bacigalupo L, Carbonaro L, et al. What is the sensitivity of mammography and dynamic MR imaging for DCIS if the whole-breast histopathology is used as a reference standard?. Radiol Med (Torino). Apr. 2008;113(3):439-51. Not eligible level of evidence. [pmid: 18414812].
2283 Sardanelli F, Fausto A, Esseridou A, et al. Gadobenate dimeglumine as a contrast agent for dynamic breast magnetic resonance imaging: effect of higher initial enhancement thresholds on diagnostic performance. Investigative radiology. Apr. 2008;43(4):236-42. Not eligible exposure. [pmid: 18340247].
2284 Sardi A, Facundus EC, Eckholdt GJ, et al. Management of cancer of the opposite breast following breast preservation. Int Surg. Oct–Dec. 1992;77(4):289-92. Not eligible target population. [pmid: 1336002].
2285 Sarff M, Schmidt K, Vetto JT. Targeted breast cancer screening in women younger than 40: results from a statewide program. Am J Surg. May. 2008;195(5):626-30. discussion 30. Not eligible target population. [pmid: 18374894].
2286 Sariego J, Byrd M, Kerstein M, et al. Factors influencing survival in infiltrating lobular carcinoma of the breast. Am Surg. Jul. 1993;59(7):405-9. Case Reports. [pmid: 8391768].
2287 Sarlos D, Frey LD, Haueisen H, et al. Radioguided occult lesion localization (ROLL) for treatment and diagnosis of malignant and premalignant breast lesions combined with sentinel node biopsy: A prospective clinical trial with 100 patients. Eur J Surg Oncol. 2008. Aug. 9. Not eligible outcomes.
2288 Sarnelli R, Squartini F. Independent submacroscopic foci of infiltrating carcinoma in breasts removed for clinical cancer. Tumori. Apr. 30. 1984;70(2):169-78. Not eligible target population. [pmid: 6203200].
2289 Sasaki Y, Minamiya Y, Takahashi N, et al. REG1A expression is an independent factor predictive of poor prognosis in patients with breast cancer. Ann Surg Oncol. Nov. 2008;15(11):3244-51. Not eligible target population. [pmid: 18781363].
2290 Sasi R, Hoo JJ, Samuel IP, et al. Chromosome aberrations and oncogene alterations in two new breast tumor cell lines. Cancer Genet Cytogenet. Feb. 1991;51(2):239-54. Not eligible outcomes. [pmid: 1704295].
2291 Satake H, Shimamoto K, Sawaki A, et al. Role of ultrasonography in the detection of intraductal spread of breast cancer: correlation with pathologic findings, mammography and MR imaging. Eur Radiol. 2000;10(11):1726-32. Not eligible target population. [pmid: 11097398].
2292 Sato M, Fukutomi T, Akashi-Tanaka S, et al. Accuracy in estimating tumor extension according to mammographic subtypes in patients with ductal carcinoma in situ. Jpn J Clin Oncol. May. 2002;32(5):157-61. Not eligible target population. [pmid: 12110641].
2293 Sato T, Akiyama F, Sakamoto G, et al. Accumulation of genetic alterations and progression of primary breast cancer. Cancer Res. Nov. 1. 1991;51(21):5794-9. Not eligible outcomes. [pmid: 1682035].
2294 Sauer T, Young K, Thoresen SO. Fine needle aspiration cytology in the work-up of mammographic and ultrasonographic findings in breast cancer screening: an attempt at differentiating in situ and invasive carcinoma. Cytopathology. Apr. 2002;13(2):101-10. Not eligible outcomes. [pmid: 11952748].
2295 Saunders G, Lakra Y, Libcke J. Comparison of needle aspiration cytologic diagnosis with excisional biopsy tissue diagnosis of palpable tumors of the breast in a community hospital. Surg Gynecol Obstet. Jun. 1991;172(6):437-40. Not eligible outcomes. [pmid: 1852078].
2296 Sauter ER, Ehya H, Babb J, et al. Biological markers of risk in nipple aspirate fluid are associated with residual cancer and tumour size. Br J Cancer. Dec. 1999;81(7):1222-7. Not eligible outcomes. [pmid: 10584885].
2297 Sauter ER, Ehya H, Mammen A, et al. Nipple aspirate cytology and pathologic parameters predict residual cancer and nodal involvement after excisional breast biopsy. Br J Cancer. Dec. 14. 2001;85(12):1952-7. Not eligible outcomes. [pmid: 11747339].
2298 Sauter ER, Klein G, Wagner-Mann C, et al. Prostate-specific antigen expression in nipple aspirate fluid is associated with advanced breast cancer. Cancer Detect Prev. 2004;28(1):27-31. Not eligible target population. [pmid: 15041074].
2299 Sauter ER, Qin W, Schlatter L, et al. Celecoxib decreases prostaglandin E2 concentrations in nipple aspirate fluid from high risk postmenopausal women and women with breast cancer. BMC Cancer. 2006;6:248. Not eligible outcomes. [pmid: 17049084].
2300 Sauter ER, Shan S, Hewett JE, et al. Proteomic analysis of nipple aspirate fluid using SELDI-TOF-MS. Int J Cancer. May. 1. 2005;114(5):791-6. Not eligible outcomes. [pmid: 15609313].
2301 Sauter ER, Winn JN, Dale PS, et al. Nipple aspirate fluid color is associated with breast cancer. Cancer Detect Prev. 2006;30(4):322-8. Not eligible target population. [pmid: 16963197].
2302 Sautter-Bihl ML, Budach W, Dunst J, et al. DEGRO practical guidelines for radiotherapy of breast cancer I: breast-conserving therapy. Strahlenther Onkol. Dec. 2007;183(12):661-6. Guidelines. [pmid: 18040609].
2303 Sauven P, Roberts A. Basal cell carcinoma of the nipple. J R Soc Med. Aug. 1983;76(8):699-701. Not eligible target population. [pmid: 6310110].
2304 Sawada S, Sato K, Kusuhara M, et al. Effect of anastrozole and tamoxifen on lipid metabolism in Japanese postmenopausal women with early breast cancer. Acta Oncol. 2005;44(2):134-41. Not eligible target population. [pmid: 15788292].
2305 Schedel H, Oellinger H, Kohlschein P, et al. Magnetic Resonance Female Breast Imaging (MRFBI) - Evaluation of the Changes in Signal Intensity over Time Pre- and Post-administration of 0.2 mmol/kg Gd-DTPA. Zentralbl Gynakol. Feb. 2002;124(2):104-10. Not eligible outcomes. [pmid: 11935495].
2306 Schiller DE, Le LW, Cho BC, et al. Factors associated with negative margins of lumpectomy specimen: potential use in selecting patients for intraoperative radiotherapy. Ann Surg Oncol. Mar. 2008;15(3):833-42. Not eligible outcomes. [pmid: 18163174].
2307 Schilling PJ, Murray JL, Markowitz AB. Novel tumor necrosis factor toxic effects. Pulmonary hemorrhage and severe hepatic dysfunction. Cancer. Jan. 1. 1992;69(1):256-60. Case Reports. [pmid: 1309306].
2308 Schlichting E, Clausen OP, Hanssen AS, et al. Ploidy and survival in resectable pancreatic cancers. A retrospective study over 9 years. Eur J Surg. Apr. 1993;159(4):229-33. Not eligible target population. [pmid: 8102544].
2309 Schmaltz J. Integrative tumor board: recurrent breast cancer or new primary. Case Presentation Integr Cancer Ther. Sep. 2003;2(3):268-70. Case Reports.
2310 Schmid BC, Rudas M, Rezniczek GA, et al. CXCR4 is expressed in ductal carcinoma in situ of the breast and in atypical ductal hyperplasia. Breast Cancer Res Treat. Apr. 2004;84(3):247-50. Not eligible outcomes. [pmid: 15026622].
2311 Schmid M, Jakesz R, Samonigg H, et al. Randomized trial of tamoxifen versus tamoxifen plus aminoglutethimide as adjuvant treatment in postmenopausal breast cancer patients with hormone receptor-positive disease: Austrian breast and colorectal cancer study group trial 6. J Clin Oncol. Mar. 15. 2003;21(6):984-90. Not eligible target population. [pmid: 12637461].
2312 Schmidberger H, Hermann RM, Hess CF, et al. Combination of anti-estrogenic therapy with radiation in breast cancer: simultaneous or sequential treatment. Onkologie. May. 2005;28(5):275-80. Review. [pmid: 15867485].
2313 Schmidt C. Molecular breast imaging: potential new tool for detecting cancers. J Natl Cancer Inst. Nov. 19. 2008;100(22):1568-70. News. [pmid: 19001598].
2314 Schmitt FC. Multistep progression from an oestrogen-dependent growth towards an autonomous growth in breast carcinogenesis. Eur J Cancer. Nov. 1995;31A(12):2049-52. Not eligible outcomes. [pmid: 8562164].
2315 Schmitt FC, Leal C, Lopes C. p53 protein expression and nuclear DNA content in breast intraductal proliferations. J Pathol. Jul. 1995;176(3):233-41. Not eligible outcomes. [pmid: 7674086].
2316 Schnitt SJ, Harris JR. Evolution of breast-conserving therapy for localized breast cancer. J Clin Oncol. Mar. 20. 2008;26(9):1395-6. no primary data. [pmid: 18349387].
2317 Schnitt SJ, Wang HH. Histologic sampling of grossly benign breast biopsies. How much is enough?. Am J Surg Pathol. Jun. 1989;13(6):505-12. Not eligible outcomes. [pmid: 2543226].
2318 Schnur JB, Montgomery GH. Hypnosis and cognitive-behavioral therapy during breast cancer radiotherapy: a case report. Am J Clin Hypn. Jan. 2008;50(3):209-15. Case Reports. [pmid: 18246853].
2319 Schobesberger M, Baltzer A, Oberli A, et al. Gene expression variation between distinct areas of breast cancer measured from paraffin-embedded tissue cores. BMC Cancer. 2008;8:343. Not eligible target population. [pmid: 19032762].
2320 Schoeller T, Huemer GM. Immediate reconstruction of the nipple/areola complex in oncoplastic surgery after central quadrantectomy. Ann Plast Surg. Dec. 2006;57(6):611-5. Not eligible exposure. [pmid: 17122544].
2321 Schoonjans JM, Brem RF. Sonographic appearance of ductal carcinoma in situ diagnosed with ultrasonographically guided large core needle biopsy: correlation with mammographic and pathologic findings. J Ultrasound Med. Jul. 2000;19(7):449-57. Not eligible outcomes. [pmid: 10898298].
2322 Schootman M, Aft R. Rural-urban differences in radiation therapy for ductal carcinoma in-situ of the breast. Breast Cancer Res Treat. Jul. 2001;68(2):117-25. Not eligible outcomes. [pmid: 11688515].
2323 Schott G, Reichel M, Junkermann H, et al. Retrospective quantification of background incidence and stage distribution of breast cancer for the mammography screening pilot project in Wiesbaden, Germany. J Cancer Res Clin Oncol. Jan. 2008;134(1):29-35. Not eligible target population. [pmid: 17602243].
2324 Schouten van der Velden AP, Peeters PH, Koot VC, et al. Clinical presentation and surgical quality in treatment of ductal carcinoma in situ of the breast. Acta Oncol. 2006;45(5):544-9. Not eligible outcomes. [pmid: 16864167].
2325 Schouten van der Velden AP, Van de Vrande SL, Boetes C, et al. Residual disease after re-excision for tumour-positive surgical margins in both ductal carcinoma in situ and invasive carcinoma of the breast: The effect of time. J Surg Oncol. Dec. 1. 2007;96(7):569-74. Not eligible outcomes. [pmid: 17680635].
2326 Schouten van der Velden AP, Van Dijck JA, Wobbes T. Variations in treatment of ductal carcinoma in situ of the breast: a population-based study in the East Netherlands. Eur J Surg Oncol. May. 2007;33(4):424-9. Not eligible target population. [pmid: 17084060].
2327 Schrading S, Kuhl CK. Mammographic, US, and MR imaging phenotypes of familial breast cancer. Radiology. Jan. 2008;246(1):58-70. Not eligible target population. [pmid: 18096529].
2328 Schrager CA, Schneider D, Gruener AC, et al. Clinical and pathological features of breast disease in Cowden’s syndrome: an underrecognized syndrome with an increased risk of breast cancer. Hum Pathol. Jan. 1998;29(1):47-53. Not eligible level of evidence. [pmid: 9445133].
2329 Schrenk P, Wolfl S, Bogner S, et al. Symmetrization reduction mammaplasty combined with sentinel node biopsy in patients operated for contralateral breast cancer. J Surg Oncol. Jul. 1. 2006;94(1):9-15. Not eligible target population. [pmid: 16788937].
2330 Schroder CP, Ruiters MH, de Jong S, et al. Detection of micrometastatic breast cancer by means of real time quantitative RT-PCR and immunostaining in perioperative blood samples and sentinel nodes. Int J Cancer. Sep. 10. 2003;106(4):611-8. Not eligible outcomes. [pmid: 12845661].
2331 Schuck A, Konemann S, Heinen K, et al. Microscopic residual disease is a risk factor in the primary treatment of breast cancer. Strahlenther Onkol. Jun. 2002;178(6):307-13. Not eligible level of evidence. [pmid: 12122786].
2332 Schuh ME, Nemoto T, Penetrante RB, et al. Intraductal carcinoma. Analysis of presentation, pathologic findings, and outcome of disease. Arch Surg. Nov. 1986;121(11):1303-7. Not eligible level of evidence. [pmid: 3022676].
2333 Schulze T, Mucke J, Markwardt J, et al. Long-term morbidity of patients with early breast cancer after sentinel lymph node biopsy compared to axillary lymph node dissection. J Surg Oncol. Feb. 1. 2006;93(2):109-19. Not eligible outcomes. [pmid: 16425290].
2334 Schurman SH, Sharon N, Goldschmidt RA, et al. Improved detection of metastases to lymph nodes and estrogen receptor determination. Arch Surg. Feb. 1990;125(2):179-82. Not eligible outcomes. [pmid: 1689142].
2335 Schuster RH, Kuske RR, Young VL, et al. Breast reconstruction in women treated with radiation therapy for breast cancer: cosmesis, complications, and tumor control. Plast Reconstr Surg. Sep. 1992;90(3):445-52. discussion 53-4. Not eligible target population. [pmid: 1325065].
2336 Schuster RH, Rotter S, Boonn W, et al. The use of tissue expanders in immediate breast reconstruction following mastectomy for cancer. Br J Plast Surg. Jul. 1990;43(4):413-8. Not eligible outcomes. [pmid: 2168231].
2337 Schusterman MA, Kroll SS, Reece GP, et al. Incidence of autoimmune disease in patients after breast reconstruction with silicone gel implants versus autogenous tissue: a preliminary report. Ann Plast Surg. Jul. 1993;31(1):1-6. Case Reports. [pmid: 8395164].
2338 Schwartz AE, Leddicotte GW, Fink RW, et al. Trace elements in noraml and malignant human breast tissue. Surgery. Aug. 1974;76(2):325-9. Not eligible outcomes. [pmid: 4367279].
2339 Schwartz GF, Finkel GC, Garcia JC, et al. Subclinical ductal carcinoma in situ of the breast. Treatment by local excision and surveillance alone. Cancer. Nov. 15. 1992;70(10):2468-74. Not eligible level of evidence. [pmid: 1330281].
2340 Schwartz GF, Patchefsky AS, Finklestein SD, et al. Nonpalpable in situ ductal carcinoma of the breast. Predictors of multicentricity and microinvasion and implications for treatment. Arch Surg. Jan. 1989;124(1):29-32. Not eligible outcomes. [pmid: 2535928].
2341 Schwartz LM, Woloshin S, Sox HC, et al. US women’s attitudes to false positive mammography results and detection of ductal carcinoma in situ: cross sectional survey. BMJ. Jun. 17. 2000;320(7250):1635-40. Not eligible target population. [pmid: 10856064].
2342 Schwartz LM, Woloshin S, Sox HC, et al. US women’s attitudes to false-positive mammography results and detection of ductal carcinoma in situ: cross-sectional survey. West J Med. Nov. 2000;173(5):307-12. Not eligible target population. [pmid: 11069862].
2343 Scott KA, Walker RA. Lack of cyclin E immunoreactivity in non-malignant breast and association with proliferation in breast cancer. Br J Cancer. 1997;76(10):1288-92. Not eligible outcomes. [pmid: 9374373].
2344 Sebek BA. Cavernous hemangioma of the female breast. Cleve Clin Q. Summer. 1984;51(2):471-4. Case Reports. [pmid: 6088123].
2345 Seemayer TA, Tremblay G, Shibata H. The unique association of mammary stromal sarcoma with intraductal carcinoma. Cancer. Aug. 1975;36(2):599-605. Case Reports. [pmid: 168959].
2346 Seitz S, Poppe K, Fischer J, et al. Detailed deletion mapping in sporadic breast cancer at chromosomal region 17p13 distal to the TP53 gene: association with clinicopathological parameters. J Pathol. Jul. 2001;194(3):318-26. Not eligible outcomes. [pmid: 11439364].
2347 Sekine K, Tsunoda-Shimizu H, Kikuchi M, et al. DCIS showing architectural distortion on the screening mammogram - comparison of mammographic and pathological findings. Breast Cancer. 2007;14(3):281-4. Not eligible outcomes. [pmid: 17690505].
2348 Selim A, Tahan SR. Microscopic localization of calcifications in and around breast carcinoma: a cautionary note for needle core biopsies. Ann Surg. Jul. 1998;228(1):95-8. Not eligible outcomes. [pmid: 9671072].
2349 Selim AA, El-Ayat G, Wells CA. Immunohistochemical localization of gross cystic disease fluid protein-15, −24 and −44 in ductal carcinoma in situ of the breast: relationship to the degree of differentiation. Histopathology. Aug. 2001;39(2):198-202. Not eligible outcomes. [pmid: 11493337].
2350 Selim AG, El-Ayat G, Wells CA. Androgen receptor expression in ductal carcinoma in situ of the breast: relation to oestrogen and progesterone receptors. J Clin Pathol. Jan. 2002;55(1):14-6. Not eligible outcomes. [pmid: 11825917].
2351 Selim AG, Ryan A, El-Ayat G, et al. Loss of heterozygosity and allelic imbalance in apocrine metaplasia of the breast: microdissection microsatellite analysis. J Pathol. Mar. 2002;196(3):287-91. Not eligible outcomes. [pmid: 11857491].
2352 Semiglazov VF, Semiglazov VV, Dashyan GA, et al. Phase 2 randomized trial of primary endocrine therapy versus chemotherapy in postmenopausal patients with estrogen receptor-positive breast cancer. Cancer. Jul. 15. 2007;110(2):244-54. Not eligible target population. [pmid: 17538978].
2353 Sener SF, Winchester DJ, Winchester DP, et al. Spectrum of mammographically detected breast cancers. Am Surg. Aug. 1999;65(8):731-5. discussion 5-6. Not eligible outcomes. [pmid: 10432082].
2354 SenGupta SK, Bukenya GB, Murthy DP. Breast cancer in Papua New Guinea: a survey of 10 years. Aust N Z J Surg. Jan. 1990;60(1):41-4. Review. [pmid: 2158291].
2355 Senn Bahls E, Dupont Lampert V, Oelschlegel C, et al. Multitarget stereotactic core-needle breast biopsy (MSBB)--an effective and safe diagnostic intervention for non-palpable breast lesions: a large prospective single institution study. Breast. Jun. 2006;15(3):339-46. Not eligible outcomes. [pmid: 16488609].
2356 Sequeiros RB, Reinikainen H, Sequeiros AM, et al. MR-guided breast biopsy and hook wire marking using a low-field (0.23 T) scanner with optical instrument tracking. Eur Radiol. Mar. 2007;17(3):813-9. Not eligible exposure. [pmid: 17021710].
2357 Serpell JW, Johnson WR. Pre-operative histological diagnosis of breast cancer. Aust N Z J Surg. Jun. 1997;67(6):325-9. Not eligible outcomes. [pmid: 9193264].
2358 Serre CM, Clezardin P, Frappart L, et al. Distribution of thrombospondin and integrin alpha V in DCIS, invasive ductal and lobular human breast carcinomas. Analysis by electron microscopy. Virchows Arch. 1995;427(4):365-72. Not eligible outcomes. [pmid: 8548120].
2359 Sessions SC, Smink RD Jr. Cutaneous angiosarcoma of the breast after segmental mastectomy and radiation therapy. Arch Surg. Nov. 1992;127(11):1362-3. Case Reports. [pmid: 1332648].
2360 Seth R, Lamyman MJ, Athanassopoulos A, et al. Too close for comfort: accidental burn following subcutaneous mastectomy and immediate implant reconstruction. J R Soc Med. Jan. 2008;101(1):39-40. Case Reports. [pmid: 18263913].
2361 Sgroi D, Koerner FC. Involvement of collagenous spherulosis by lobular carcinoma in situ. Potential confusion with cribriform ductal carcinoma in situ. Am J Surg Pathol. Dec. 1995;19(12):1366-70. Not eligible outcomes. [pmid: 7503359].
2362 Shafiq J, Delaney G, Barton MB. An evidence-based estimation of local control and survival benefit of radiotherapy for breast cancer. Radiother Oncol. Jul. 2007;84(1):11-7. Review. [pmid: 17399830].
2363 Shah AP, Dickler A, Kirk MC, et al. Case report and dosimetric analysis of an axillary recurrence after partial breast irradiation with mammosite catheter. Med Dosim. Autumn. 2008;33(3):222-5. Case Reports. [pmid: 18674687].
2364 Shah S, Doyle K, Lange EM, et al. Breast cancer recurrences in elderly patients after lumpectomy. Am Surg. Aug. 2002;68(8):735-9. Not eligible target population. [pmid: 12206612].
2365 Shah VI, Flowers CI, Douglas-Jones AG, et al. Immunohistochemistry increases the accuracy of diagnosis of benign papillary lesions in breast core needle biopsy specimens. Histopathology. May. 2006;48(6):683-91. Not eligible outcomes. [pmid: 16681684].
2366 Shannon KM, Lubratovich ML, Finkelstein DM, et al. Model-based predictions of BRCA1/2 mutation status in breast carcinoma patients treated at an academic medical center. Cancer. Jan. 15. 2002;94(2):305-13. Not eligible target population. [pmid: 11900216].
2367 Shapiro JM, Avigan DE, Warshofsky MK, et al. Acute cor pulmonale due to tumor emboli. Diagnosis by pulmonary artery catheterization. N Y State J Med. Mar. 1993;93(3):197-8. Case Reports. [pmid: 8384350].
2368 Shapiro S. Periodic screening for breast cancer: the HIP Randomized Controlled Trial. Health Insurance Plan J Natl Cancer Inst Monogr. 1997:27-30. Not eligible outcomes.
2369 Sharma P, Klemp JR, Simonsen M, et al. Failure of high risk women to produce nipple aspirate fluid does not exclude detection of cytologic atypia in random periareolar fine needle aspiration specimens. Breast Cancer Res Treat. Sep. 2004;87(1):59-64. Not eligible target population. [pmid: 15377851].
2370 Sharma R, Dietz J, Wright H, et al. Comparative analysis of minimally invasive microductectomy versus major duct excision in patients with pathologic nipple discharge. Surgery. Oct. 2005;138(4):591-6. discussion 6-7. Not eligible outcomes. [pmid: 16269286].
2371 Sharp K. Atypical fatigue. Clin J Oncol Nurs. Oct. 2007;11(5):628-30. Case Reports. [pmid: 17962170].
2372 Shearman CP, Watts GT. Paget’s disease of the nipple after subcutaneous mastectomy for cancer with primary reconstruction. Ann R Coll Surg Engl. Jan. 1986;68(1):17-8. Not eligible target population. [pmid: 3004315].
2373 Sheen-Chen SM, Chen HS, Chen WJ, et al. Paget disease of the breast--an easily overlooked disease. J Surg Oncol. Apr. 2001;76(4):261-5. Not eligible target population. [pmid: 11320517].
2374 Sheen-Chen SM, Chen YS, Chou FF, et al. Primary squamous cell carcinoma of the breast. South Med J. Feb. 1992;85(2):207-9. Case Reports. [pmid: 1310819].
2375 Sheen-Chen SM, Chou FF. A comparison between scalpel and electrocautery in modified radical mastectomy. Eur J Surg. Sep. 1993;159(9):457-9. Not eligible target population. [pmid: 8274552].
2376 Shekhar MP, Tait L, Pauley RJ, et al. Comedo-ductal carcinoma in situ: A paradoxical role for programmed cell death. Cancer Biol Ther. Nov. 12. 2008;7(11). Not eligible outcomes.
2377 Shen CY, Yu JC, Lo YL, et al. Genome-wide search for loss of heterozygosity using laser capture microdissected tissue of breast carcinoma: an implication for mutator phenotype and breast cancer pathogenesis. Cancer Res. Jul. 15. 2000;60(14):3884-92. Not eligible outcomes. [pmid: 10919664].
2378 Shen J, Gammon MD, Terry MB, et al. Genetic polymorphisms in the cyclooxygenase-2 gene, use of nonsteroidal anti-inflammatory drugs, and breast cancer risk. Breast Cancer Research. 2006;8(6):R71. Not eligible outcomes. [pmid: 17181859].
2379 Shen KL, Yang LS, Hsieh HF, et al. Microsatellite alterations on human chromosome 11 in in situ and invasive breast cancer: a microdissection microsatellite analysis and correlation with p53, ER (estrogen receptor), and PR (progesterone receptor) protein immunoreactivity. J Surg Oncol. Jun. 2000;74(2):100-7. Not eligible outcomes. [pmid: 10914818].
2380 Sheren-Manoff M, Shin SJ, Su D, et al. Reduced lecithin:retinol acyltransferase expression in human breast cancer. Int J Oncol. Nov. 2006;29(5):1193-9. Not eligible outcomes. [pmid: 17016651].
2381 Sheth D, Wesen CA, Schroder D, et al. The advanced breast biopsy instrumentation (ABBI) experience at a community hospital. Am Surg. Aug. 1999;65(8):726-9. discussion 9-30. Not eligible outcomes. [pmid: 10432081].
2382 Shibuya R, Suzuki T, Miki Y, et al. Intratumoral concentration of sex steroids and expression of sex steroid-producing enzymes in ductal carcinoma in situ of human breast. Endocrine-related cancer. Mar. 2008;15(1):113-24. Not eligible outcomes. [pmid: 18310280].
2383 Shim V, Gauthier ML, Sudilovsky D, et al. Cyclooxygenase-2 expression is related to nuclear grade in ductal carcinoma in situ and is increased in its normal adjacent epithelium. Cancer Res. May. 15. 2003;63(10):2347-50. Not eligible outcomes. [pmid: 12750248].
2384 Shin HJ, Kim HH, Kim SM, et al. Screening-detected and symptomatic ductal carcinoma in situ: differences in the sonographic and pathologic features. AJR Am J Roentgenol. Feb. 2008;190(2):516-25. Not eligible outcomes. [pmid: 18212241].
2385 Shin JH, Han BK, Choe YH, et al. Targeted ultrasound for MR-detected lesions in breast cancer patients. Korean J Radiol. Nov–Dec. 2007;8(6):475-83. Not eligible outcomes. [pmid: 18071277].
2386 Shin JH, Han BK, Choe YH, et al. Ultrasonographic detection of occult cancer in patients after surgical therapy for breast cancer. J Ultrasound Med. May. 2005;24(5):643-9. Not eligible outcomes. [pmid: 15840796].
2387 Shin SJ, Rosen PP. Excisional biopsy should be performed if lobular carcinoma in situ is seen on needle core biopsy. Arch Pathol Lab Med. Jun. 2002;126(6):697-701. Not eligible outcomes. [pmid: 12033958].
2388 Shin SJ, Rosen PP. Carcinoma arising from preexisting pregnancy-like and cystic hypersecretory hyperplasia lesions of the breast: a clinicopathologic study of 9 patients. Am J Surg Pathol. Jun. 2004;28(6):789-93. Not eligible target population. [pmid: 15166671].
2389 Shiraishi A, Kurosaki Y, Maehara T, et al. Extension of ductal carcinoma in situ: histopathological association with MR imaging and mammography. Magn Reson Med Sci. Dec. 31. 2003;2(4):159-63. Not eligible level of evidence. [pmid: 16222109].
2390 Sho M, Nakajima Y, Kanehiro H, et al. Pattern of recurrence after resection for intraductal papillary mucinous tumors of the pancreas. World J Surg. Aug. 1998;22(8):874-8. Not eligible target population. [pmid: 9673562].
2391 Shoker BS, Jarvis C, Clarke RB, et al. Abnormal regulation of the oestrogen receptor in benign breast lesions. J Clin Pathol. Oct. 2000;53(10):778-83. Not eligible target population. [pmid: 11064673].
2392 Shoker BS, Jarvis C, Sibson DR, et al. Oestrogen receptor expression in the normal and pre-cancerous breast. J Pathol. Jul. 1999;188(3):237-44. Not eligible outcomes. [pmid: 10419589].
2393 Shpitz B, Bomstein Y, Zehavi T, et al. Topoisomerase IIalpha expression in ductal carcinoma in situ of the breast: a preliminary study. Hum Pathol. Oct. 2000;31(10):1249-54. Not eligible outcomes. [pmid: 11070118].
2394 Shpitz B, Zimlichman S, Zemer R, et al. Telomerase activity in ductal carcinoma in situ of the breast. Breast Cancer Res Treat. Nov. 1999;58(1):65-9. Not eligible outcomes. [pmid: 10634519].
2395 Shugg D, White VM, Kitchen PR, et al. Surgical management of ductal carcinoma in situ in Australia in 1995. ANZ J Surg. Oct. 2002;72(10):708-15. Not eligible outcomes. [pmid: 12534380].
2396 Sidawy MK, Stoler MH, Frable WJ, et al. Interobserver variability in the classification of proliferative breast lesions by fine-needle aspiration: results of the Papanicolaou Society of Cytopathology Study. Diagn Cytopathol. Feb. 1998;18(2):150-65. Not eligible outcomes. [pmid: 9484645].
2397 Sidebotham HJ, Al-Talib RK, Theaker JM. Lesson of the month. The value of immunohistochemistry in breast pathology. Histopathology. Aug. 2003;43(2):194-5. Case Reports. [pmid: 12877736].
2398 Sidhua S, Siu KK, Falzon G, et al. X-ray scattering for classifying tissue types associated with breast disease. Med Phys. Oct. 2008;35(10):4660-70. Not eligible outcomes. [pmid: 18975712].
2399 Sigal-Zafrani B, Muller K, El Khoury C, et al. Vacuum-assisted large-core needle biopsy (VLNB) improves the management of patients with breast microcalcifications - analysis of 1009 cases. Eur J Surg Oncol. Apr. 2008;34(4):377-81. Not eligible outcomes. [pmid: 17604937].
2400 Sigal-Zafrani B, Muller K, El Khoury C, et al. Vacuum-assisted large-core needle biopsy (VLNB) improves the management of patients with breast microcalcifications - analysis of 1009 cases. European Journal of Surgical Oncology. Apr. 2008;34(4):377-81. Not eligible exposure. [pmid: 17604937].
2401 Sigurdson AJ, Hauptmann M, Chatterjee N, et al. Kin-cohort estimates for familial breast cancer risk in relation to variants in DNA base excision repair, BRCA1 interacting and growth factor genes. BMC Cancer. 2004;4(1):9. Not eligible outcomes. [pmid: 15113441].
2402 Siitonen SM, Kononen JT, Helin HJ, et al. Reduced E-cadherin expression is associated with invasiveness and unfavorable prognosis in breast cancer. Am J Clin Pathol. Apr. 1996;105(4):394-402. Not eligible outcomes. [pmid: 8604681].
2403 Sijens PE, Wijrdeman HK, Moerland MA, et al. Human breast cancer in vivo: H-1 and P-31 MR spectroscopy at 1.5 T. Radiology. Dec. 1988;169(3):615-20. Not eligible outcomes. [pmid: 2847230].
2404 Silver SA, Tavassoli FA. Mammary ductal carcinoma in situ with microinvasion. Cancer. Jun. 15. 1998;82(12):2382-90. Not eligible level of evidence. [pmid: 9635531].
2405 Silverstein MJ. Intraductal breast carcinoma. Two decades of progress?. Am J Clin Oncol. Dec. 1991;14(6):534-7. no primary data. [pmid: 1659784].
2406 Silverstein MJ, Gierson ED, Colburn WJ, et al. Axillary lymphadenectomy for intraductal carcinoma of the breast. Surg Gynecol Obstet. Mar. 1991;172(3):211-4. Not eligible outcomes. [pmid: 1847243].
2407 Silverstein MJ, Gierson ED, Gamagami P, et al. Breast cancer diagnosis and prognosis in women augmented with silicone gel-filled implants. Cancer. Jul. 1. 1990;66(1):97-101. not eligible target population. [pmid: 2162244].
2408 Silverstein MJ, Handel N, Gamagami P, et al. Breast cancer in women after augmentation mammoplasty. Arch Surg. Jun. 1988;123(6):681-5. Not eligible exposure. [pmid: 2835940].
2409 Silverstein MJ, Lagios MD. Benefits of irradiation for DCIS: a Pyrrhic victory. Lancet. Feb. 12. 2000;355(9203):510-1. Comment. [pmid: 10682994].
2410 Silverstein MJ, Parker R, Grotting JC, et al. Ductal carcinoma in situ (DCIS) of the breast: diagnostic and therapeutic controversies. J Am Coll Surg. Feb. 2001;192(2):196-214. No primary data. [pmid: 11220720].
2411 Silverstein MJ, Skinner KA, Lomis TJ. Predicting axillary nodal positivity in 2282 patients with breast carcinoma. World J Surg. Jun. 2001;25(6):767-72. Not eligible target population. [pmid: 11376414].
2412 Sim LS, Kei PL. Upright stereotactic vacuum-assisted needle biopsy of suspicious breast microcalcifications. Journal of Medical Imaging & Radiation Oncology. Aug. 2008;52(4):358-64. Not eligible exposure. [pmid: 18811759].
2413 Simmons RM, Hollenbeck ST, Latrenta GS. Areola-sparing mastectomy with immediate breast reconstruction. Ann Plast Surg. Dec. 2003;51(6):547-51. Not eligible target population. [pmid: 14646645].
2414 Simmons RM, Hollenbeck ST, Latrenta GS. Two-year follow-up of areola-sparing mastectomy with immediate reconstruction. Am J Surg. Oct. 2004;188(4):403-6. Not eligible target population. [pmid: 15474435].
2415 Simpson JF. Update on atypical epithelial hyperplasia and ductal carcinoma in situ. Pathology. Jan. 2009;41(1):36-9. Comment. [pmid: 19089738].
2416 Simpson JF, O’Malley F, Dupont WD, et al. Heterogeneous expression of nm23 gene product in noninvasive breast carcinoma. Cancer. May. 1. 1994;73(9):2352-8. Not eligible outcomes. [pmid: 7513249].
2417 Simsir A, Waisman J, Cangiarella J. Fibroadenomas with atypia: causes of under- and overdiagnosis by aspiration biopsy. Diagn Cytopathol. Nov. 2001;25(5):278-84. Not eligible target population. [pmid: 11747216].
2418 Singer C, Hudelist G, Fuchs E, et al. Incomplete surgical resection of DCIS results in activation of HER-2 in residual breast cancer cells. Endocr Relat Cancer. 2009. Jan. 7. Not eligible level of evidence.
2419 Singer JA. Residual breast cancer at a distance from the primary tumor. Am Surg. Jul. 1993;59(7):435-7. Not eligible outcomes. [pmid: 8391770].
2420 Singh N, Theaker JM. Calcium oxalate crystals (Weddellite) within the secretions of ductal carcinoma in situ--a rare phenomenon. J Clin Pathol. Feb. 1999;52(2):145-6. Case Reports. [pmid: 10396244].
2421 Singh SM, Longmire WP Jr, Reber HA. Surgical palliation for pancreatic cancer. The UCLA experience. Ann Surg. Aug. 1990;212(2):132-9. Not eligible target population. [pmid: 1695834].
2422 Singletary E, Lieberman R, Atkinson N, et al. Novel translational model for breast cancer chemoprevention study: accrual to a presurgical intervention with tamoxifen and N-[4-hydroxyphenyl] retinamide. Cancer Epidemiol Biomarkers Prev. Oct. 2000;9(10):1087-90. Not eligible outcomes. [pmid: 11045792].
2423 Singletary SE, Atkinson EN, Hoque A, et al. Phase II clinical trial of N-(4-Hydroxyphenyl)retinamide and tamoxifen administration before definitive surgery for breast neoplasia. Clin Cancer Res. Sep. 2002;8(9):2835-42. Not eligible outcomes. [pmid: 12231524].
2424 Sinha MR, Prasad SB. Bilateral Paget’s disease of the nipple. J Indian Med Assoc. Jan. 16. 1983;80(2):27-8. Not eligible target population. [pmid: 6308099].
2425 Sinow JD, Cunningham BL. Postmastectomy brachial plexus injury exacerbated by tissue expansion. Ann Plast Surg. Oct. 1991;27(4):368-70. Case Reports. [pmid: 1663326].
2426 Sioufi A, Gauducheau N, Pineau V, et al. Absolute bioavailability of letrozole in healthy postmenopausal women. Biopharm Drug Dispos. Dec. 1997;18(9):779-89. Not eligible target population. [pmid: 9429742].
2427 Sitakalin C, Ackerman AB. Mammary and extramammary Paget’s disease. Am J Dermatopathol. Aug. 1985;7(4):335-40. Not eligible target population. [pmid: 3026195].
2428 Sitterding SM, Wiseman WR, Schiller CL, et al. AlphaB-crystallin: a novel marker of invasive basal-like and metaplastic breast carcinomas. Annals of Diagnostic Pathology. Feb. 2008;12(1):33-40. Not eligible outcomes. [pmid: 18164413].
2429 Siziopikou KP, Prioleau JE, Harris JR, et al. bcl-2 expression in the spectrum of preinvasive breast lesions. Cancer. Feb. 1. 1996;77(3):499-506. Not eligible outcomes. [pmid: 8630957].
2430 Skalova A, Michal M, Simpson RH, et al. Sclerosing polycystic adenosis of parotid gland with dysplasia and ductal carcinoma in situ. Report of three cases with immunohistochemical and ultrastructural examination. Virchows Arch. Jan. 2002;440(1):29-35. Case Reports. [pmid: 11942573].
2431 Skandarajah AR, Field L, Yuen Larn Mou A, et al. Benign papilloma on core biopsy requires surgical excision. Annals of Surgical Oncology. Aug. 2008;15(8):2272-7. Not eligible-target population. [pmid: 18473143].
2432 Skjorten FJ, Skaane P, Jacobsen U, et al. The histopathology of non-palpable breast lesions detected by clinical mammography. Eur J Surg Oncol. Dec. 1990;16(6):475-80. Not eligible outcomes. [pmid: 2253791].
2433 Slater M, Danieletto S, Pooley M, et al. Differentiation between cancerous and normal hyperplastic lobules in breast lesions. Breast Cancer Res Treat. Jan. 2004;83(1):1-10. Not eligible outcomes. [pmid: 14997049].
2434 Slavin SA, Howrigan PJ, Goldwyn RM. Pseudocyst formation after rectus flap breast reconstruction: diagnosis and treatment. Plast Reconstr Surg. Apr. 1989;83(4):670-5. Case Reports. [pmid: 2538852].
2435 Slavin SA, Schnitt SJ, Duda RB, et al. Skin-sparing mastectomy and immediate reconstruction: oncologic risks and aesthetic results in patients with early-stage breast cancer. Plast Reconstr Surg. Jul. 1998;102(1):49-62. Not eligible level of evidence. [pmid: 9655407].
2436 Sliwinski T, Krupa R, Majsterek I, et al. Polymorphisms of the BRCA2 and RAD51 genes in breast cancer. Breast Cancer Res Treat. Nov. 2005;94(2):105-9. Not eligible outcomes. [pmid: 16261408].
2437 Sloane JP, Mayers MM. Carcinoma and atypical hyperplasia in radial scars and complex sclerosing lesions: importance of lesion size and patient age. Histopathology. Sep. 1993;23(3):225-31. Not eligible level of evidence. [pmid: 8225240].
2438 Smeds J, Warnberg F, Norberg T, et al. Ductal carcinoma in situ of the breast with different histopathological grades and corresponding new breast tumour events: analysis of loss of heterozygosity. Acta Oncol. 2005;44(1):41-9. Not eligible outcomes. [pmid: 15848905].
2439 Smith BL, Bertagnolli M, Klein BB, et al. Evaluation of the contralateral breast. The role of biopsy at the time of treatment of primary breast cancer. Ann Surg. Jul. 1992;216(1):17-21. Not eligible target population. [pmid: 1321595].
2440 Smith DM, Ness MJ, Landmark JD, et al. Recurrent neurologic symptoms during peripheral stem cell apheresis in two patients with intracranial metastases. J Clin Apher. 1990;5(2):70-3. Case Reports. [pmid: 2153664].
2441 Smith DM Jr, Peters TG, Donegan WL. Montgomery’s areolar tubercle. A light microscopic study. Arch Pathol Lab Med. Feb. 1982;106(2):60-3. Not eligible outcomes. [pmid: 6277270].
2442 Smith IE. Letrozole versus tamoxifen in the treatment of advanced breast cancer and as neoadjuvant therapy. J Steroid Biochem Mol Biol. Sep. 3. 2003:86-5. 289. 93. Not eligible target population.
2443 Smith IE, A’Hern RP, Coombes GA, et al. A novel continuous infusional 5-fluorouracil-based chemotherapy regimen compared with conventional chemotherapy in the neo-adjuvant treatment of early breast cancer: 5 year results of the TOPIC trial. Ann Oncol. May. 2004;15(5):751-8. Not eligible target population. [pmid: 15111342].
2444 Smith IE, Dowsett M, Ebbs SR, et al. Neoadjuvant treatment of postmenopausal breast cancer with anastrozole, tamoxifen, or both in combination: the Immediate Preoperative Anastrozole, Tamoxifen, or Combined with Tamoxifen (IMPACT) multicenter double-blind randomized trial. J Clin Oncol. Aug. 1. 2005;23(22):5108-16. Not eligible target population. [pmid: 15998903].
2445 Smith IE, Harris AL, Morgan M, et al. Tamoxifen versus aminoglutethimide in advanced breast carcinoma: a randomized cross-over trial. Br Med J (Clin Res Ed). Nov. 28. 1981;283(6304):1432-4. Not eligible target population.
2446 Smith IE, Harris AL, Morgan M, et al. Tamoxifen versus aminoglutethimide versus combined tamoxifen and aminoglutethimide in the treatment of advanced breast carcinoma. Cancer Res. Aug. 1982;42(8 Suppl):3430s-3s. Not eligible target population. [pmid: 7044525].
2447 Smith IE, Walsh G, Skene A, et al. A phase II placebo-controlled trial of neoadjuvant anastrozole alone or with gefitinib in early breast cancer. J Clin Oncol. Sep. 1. 2007;25(25):3816-22. Not eligible target population. [pmid: 17679728].
2448 Smith KL, Adank M, Kauff N, et al. BRCA mutations in women with ductal carcinoma in situ. Clin Cancer Res. Jul. 15. 2007;13(14):4306-10. Not eligible outcomes. [pmid: 17634561].
2449 Smitt MC, Birdwell RL, Goffinet DR. Breast electron boost planning: comparison of CT and US. Radiology. Apr. 2001;219(1):203-6. not eligible outcomes. [pmid: 11274557].
2450 Smitt MC, Horst K. Association of clinical and pathologic variables with lumpectomy surgical margin status after preoperative diagnosis or excisional biopsy of invasive breast cancer. Ann Surg Oncol. Mar. 2007;14(3):1040-4. Not eligible target population. [pmid: 17203329].
2451 Sneige N, Lim SC, Whitman GJ, et al. Atypical ductal hyperplasia diagnosis by directional vacuum-assisted stereotactic biopsy of breast microcalcifications. Considerations for surgical excision. Am J Clin Pathol. Feb. 2003;119(2):248-53. Not eligible outcomes. [pmid: 12579995].
2452 Sneige N, Staerkel GA. Fine-needle aspiration cytology of ductal hyperplasia with and without atypia and ductal carcinoma in situ. Hum Pathol. May. 1994;25(5):485-92. Not eligible outcomes. [pmid: 8200642].
2453 Sneige N, Wang J, Baker BA, et al. Clinical, histopathologic, and biologic features of pleomorphic lobular (ductal-lobular) carcinoma in situ of the breast: a report of 24 cases. Mod Pathol. Oct. 2002;15(10):1044-50. Not eligible outcomes. [pmid: 12379750].
2454 Sneige N, White VA, Katz RL, et al. Ductal carcinoma-in-situ of the breast: fine-needle aspiration cytology of 12 cases. Diagn Cytopathol. 1989;5(4):371-7. Not eligible outcomes. [pmid: 2558863].
2455 Snell MJ, Ostrow LB, DuBois JJ, et al. Needle-localized biopsy of occult breast lesions: an update. Mil Med. Feb. 1992;157(2):61-4. Not eligible outcomes. [pmid: 1318524].
2456 Sng KW, Ng EH, Ng FC, et al. Spectrum of abnormal mammographic findings and their predictive value for malignancy in Singaporean women from a population screening trial. Ann Acad Med Singapore. Jul. 2000;29(4):457-62. Not eligible outcomes. [pmid: 11056775].
2457 Soderstrom CE, Harms SE, Copit DS, et al. Three-dimensional RODEO breast MR imaging of lesions containing ductal carcinoma in situ. Radiology. Nov. 1996;201(2):427-32. Not eligible outcomes. [pmid: 8888235].
2458 Soderstrom J, Arnerlov C, Emdin SO, et al. Linell classification of breast cancer morphology compared to histologic grading, S-phase fraction and DNA-ploidy. Pathol Res Pract. 1997;193(7):485-90. Not eligible outcomes. [pmid: 9342754].
2459 Sohn V, Arthurs Z, Herbert G, et al. Atypical ductal hyperplasia: improved accuracy with the 11-gauge vacuum-assisted versus the 14-gauge core biopsy needle. Ann Surg Oncol. Sep. 2007;14(9):2497-501. Not eligible outcomes. [pmid: 17564749].
2460 Solin LJ, Fourquet A, McCormick B, et al. Salvage treatment for local recurrence following breast-conserving surgery and definitive irradiation for ductal carcinoma in situ (intraductal carcinoma) of the breast. Int J Radiat Oncol Biol Phys. Aug. 30. 1994;30(1):3-9. Not eligible target population. [pmid: 8083125].
2461 Solin LJ, Fourquet A, Vicini FA, et al. Salvage treatment for local recurrence after breast-conserving surgery and radiation as initial treatment for mammographically detected ductal carcinoma in situ of the breast. Cancer. Mar. 15. 2001;91(6):1090-7. Not eligible target population. [pmid: 11267953].
2462 Solin LJ, Fourquet A, Vicini FA, et al. Salvage treatment for local or local-regional recurrence after initial breast conservation treatment with radiation for ductal carcinoma in situ. Eur J Cancer. Aug. 2005;41(12):1715-23. Not eligible target population. [pmid: 16043350].
2463 Solin LJ, Fowble BL, Schultz DJ, et al. The impact of mammography on the patterns of patients referred for definitive breast irradiation. Cancer. Mar. 1. 1990;65(5):1085-9. Not eligible outcomes. [pmid: 2154319].
2464 Solin LJ, Fowble BL, Schultz DJ, et al. The significance of the pathology margins of the tumor excision on the outcome of patients treated with definitive irradiation for early stage breast cancer. Int J Radiat Oncol Biol Phys. Jul. 1991;21(2):279-87. Not eligible target population. [pmid: 1648041].
2465 Solin LJ, Fowble BL, Schultz DJ, et al. Definitive irradiation for intraductal carcinoma of the breast. Int J Radiat Oncol Biol Phys. Oct. 1990;19(4):843-50. Not eligible level of evidence. [pmid: 2170306].
2466 Solin LJ, Fowble BL, Yeh IT, et al. Microinvasive ductal carcinoma of the breast treated with breast-conserving surgery and definitive irradiation. Int J Radiat Oncol Biol Phys. 1992;23(5):961-8. Not eligible target population. [pmid: 1322388].
2467 Solorzano CC, Middleton LP, Hunt KK, et al. Treatment and outcome of patients with intracystic papillary carcinoma of the breast. Am J Surg. Oct. 2002;184(4):364-8. Not eligible target population. [pmid: 12383904].
2468 Somani A, Hwang JS, Chaiwun B, et al. Fine needle aspiration cytology in young women with breast cancer: diagnostic difficulties. Pathology. Jun. 2008;40(4):359-64. Not eligible outcomes. [pmid: 18446625].
2469 Somerville JE, Clarke LA, Biggart JD. c-erbB-2 overexpression and histological type of in situ and invasive breast carcinoma. J Clin Pathol. Jan. 1992;45(1):16-20. Not eligible outcomes. [pmid: 1346789].
2470 Somiari SB, Somiari RI, Heckman CM, et al. Circulating MMP2 and MMP9 in breast cancer -- potential role in classification of patients into low risk, high risk, benign disease and breast cancer categories. Int J Cancer. Sep. 15. 2006;119(6):1403-11. Not eligible outcomes. [pmid: 16615109].
2471 Song J, Bai J, Yang W, et al. Expression and clinicopathological significance of oestrogen-responsive ezrin-radixin-moesin-binding phosphoprotein 50 in breast cancer. Histopathology. Jul. 2007;51(1):40-53. Not eligible outcomes. [pmid: 17593079].
2472 Sonnenfeld MR, Frenna TH, Weidner N, et al. Lobular carcinoma in situ: mammographic-pathologic correlation of results of needle-directed biopsy. Radiology. Nov. 1991;181(2):363-7. Not eligible outcomes. [pmid: 1924773].
2473 Soo MS, Baker JA, Rosen EL. Sonographic detection and sonographically guided biopsy of breast microcalcifications. AJR Am J Roentgenol. Apr. 2003;180(4):941-8. Not eligible outcomes. [pmid: 12646433].
2474 Soo MS, Williford ME, Walsh R, et al. Papillary carcinoma of the breast: imaging findings. AJR Am J Roentgenol. Feb. 1995;164(2):321-6. Not eligible outcomes. [pmid: 7839962].
2475 Sookhan N, Boughey JC, Walsh MF, et al. Nipple-sparing mastectomy--initial experience at a tertiary center. Am J Surg. Oct. 2008;196(4):575-7. Not eligible outcomes. [pmid: 18809066].
2476 Soomro S, Shousha S, Taylor P, et al. c-erbB-2 expression in different histological types of invasive breast carcinoma. J Clin Pathol. Mar. 1991;44(3):211-4. Not eligible outcomes. [pmid: 1672872].
2477 Soomro S, Taylor P, Shepard HM, et al. c-erbB-2 oncoprotein in screen-detected breast carcinoma: an immunohistological study. Int J Cancer. Aug. 19. 1993;55(1):63-5. Not eligible target population. [pmid: 8102130].
2478 Soon PS, Vallentine J, Palmer A, et al. Echogenicity of breast cancer: is it of prognostic value. Breast. Jun. 2004;13(3):194-9. Not eligible outcomes. [pmid: 15177421].
2479 Soria G, Yaal-Hahoshen N, Azenshtein E, et al. Concomitant expression of the chemokines RANTES and MCP-1 in human breast cancer: a basis for tumor-promoting interactions. Cytokine. Oct. 2008;44(1):191-200. Not eligible outcomes. [pmid: 18790652].
2480 Soriano Z, Pardee JD. M34 actin regulatory protein is a sensitive diagnostic marker for early- and late-stage mammary carcinomas. Clin Cancer Res. Jul. 1. 2004;10(13):4437-43. Not eligible outcomes. [pmid: 15240534].
2481 Sotome K, Yamamoto Y, Hirano A, et al. The role of contrast enhanced MRI in the diagnosis of non-mass image-forming lesions on breast ultrasonography. Breast Cancer. 2007;14(4):371-80. Not eligible target population. [pmid: 17986802].
2482 Souder C, Leitzel K, Ali SM, et al. Serum epidermal growth factor receptor/HER-2 predicts poor survival in patients with metastatic breast cancer. Cancer. Nov. 15. 2006;107(10):2337-45. Not eligible target population. [pmid: 17048231].
2483 Soutar RL, Dawson AA. Breast carcinoma and secondary acute lymphoblastic leukaemia responding to leukaemic chemotherapy. Clin Lab Haematol. 1990;12(3):355-6. Case Reports. [pmid: 2176958].
2484 Sparks CA. Using ductoscopy to detect breast mass at an early stage. AORN J. Nov. 2002;76(5):851-4. Case Reports. [pmid: 12463084].
2485 Spear SL, Hoffman S. Relocation of the displaced nipple-areola by reciprocal skin grafts. Plast Reconstr Surg. Apr. 1998;101(5):1355-8. Case Reports. [pmid: 9529226].
2486 Speers C, Brown P. Breast cancer prevention using calcium and vitamin D: a bright future. J Natl Cancer Inst. Nov. 19. 2008;100(22):1562-4. Editorial. [pmid: 19001596].
2487 Springer GF, Desai PR, Banatwala I. Blood group MN antigens and precursors in normal and malignant human breast glandular tissue. J Natl Cancer Inst. Feb. 1975;54(2):335-9. Not eligible outcomes. [pmid: 163330].
2488 Springer HA. Reduction mammaplasty with discovery of occult breast carcinoma in twins: case reports. Plast Reconstr Surg. Jul. 1978;62(1):122-4. Case Reports. [pmid: 208091].
2489 Srivastava A, Webster DJ. Isolated nipple recurrence seventeen years after subcutaneous mastectomy for breast cancer--a case report. Eur J Surg Oncol. Oct. 1987;13(5):459-61. Case Reports. [pmid: 2822494].
2490 St Laurent M, Frazee RC. Radical pancreatic resection for benign and malignant disease. Am Surg. Feb. 1993;59(2):69-73. Not eligible target population. [pmid: 8386488].
2491 Stacey SN, Sulem P, Johannsson OT, et al. The BARD1 Cys557Ser variant and breast cancer risk in Iceland. PLoS Med. Jul. 2006;3(7):e217. Not eligible target population. [pmid: 16768547].
2492 Stacey-Clear A, McCarthy KA, Hall DA, et al. Breast cancer survival among women under age 50: is mammography detrimental. Lancet. Oct. 24. 1992;340(8826):991-4. Not eligible target population. [pmid: 1357448].
2493 Stacey-Clear A, McCarthy KA, Hall DA, et al. Mammographically detected breast cancer: location in women under 50 years old. Radiology. Mar. 1993;186(3):677-80. Not eligible outcomes. [pmid: 8381550].
2494 Stanislawek A, Kurylcio L, Krasuska ME. Surgical treatment in Paget’s disease of the breast. Ann Univ Mariae Curie Sklodowska [Med]. 2002;57(1):444-8. Not eligible target population.
2495 Staradub VL, Hsieh YC, Clauson J, et al. Factors that influence surgical choices in women with breast carcinoma. Cancer. Sep. 15. 2002;95(6):1185-90. Not eligible outcomes. [pmid: 12216083].
2496 Staren ED, Klepac S, Smith AP, et al. The dilemma of delayed cellulitis after breast conservation therapy. Arch Surg. Jun. 1996;131(6):651-4. No associated hypothesis tested. [pmid: 8645074].
2497 Stark A, Prince A, Kucera G, et al. Evaluating post-treatment screening in women with breast cancer. Cancer Pract. Sep–Oct. 2002;10(5):228-33. Not eligible outcomes. [pmid: 12236835].
2498 Stastny J, Prasad R, Fosslien E. Tissue proteins in breast cancer, as studied by use of two-dimensional electrophoresis. Clin Chem. Dec. 1984;30(12 Pt 1):1914-8. Not eligible outcomes. [pmid: 6094037].
2499 Stearns V, Coop A, Singh B, et al. A pilot surrogate end point biomarker trial of perillyl alcohol in breast neoplasia. Clin Cancer Res. Nov. 15. 2004;10(22):7583-91. Not eligible outcomes. [pmid: 15569989].
2500 Stein LF, Zisman G, Rapelyea JA, et al. Lobular carcinoma in situ of the breast presenting as a mass. AJR Am J Roentgenol. Jun. 2005;184(6):1799-801. Case Reports. [pmid: 15908533].
2501 Stephens RL, Schimke RN. Case report: breast cancer in males--a genetic consideration. Am J Med Sci. Aug. 1992;304(2):91-2. Not eligible target population. [pmid: 1323932].
2502 Stephenson TJ, Hird PM, Laing RW, et al. Nodular basement membrane deposits in breast carcinoma and atypical ductal hyperplasia: mimics of collagenous spherulosis. Pathologica. Jun. 1994;86(3):234-9. Case Reports. [pmid: 7808791].
2503 Sterrett G, Oliver D, Frayne J, et al. Stereotactic fine needle aspiration biopsy (SFNB) of breast: preliminary results in Perth with the TRC mammotest machine. Cytological aspects. Pathology. Oct. 1991;23(4):302-10. Not eligible outcomes. [pmid: 1664514].
2504 Stetler-Stevenson W, Lurain JR, Murad T. Placental site trophoblastic tumor associated with immature ovarian teratoma. Int J Gynaecol Obstet. Jul. 1990;32(3):275-9. Case Reports. [pmid: 1972122].
2505 Stewart AJ, O’Farrell DA, Cormack RA, et al. Dose volume histogram analysis of normal structures associated with accelerated partial breast irradiation delivered by high dose rate brachytherapy and comparison with whole breast external beam radiotherapy fields. Radiat Oncol. 2008;3:39. Not eligible target population. [pmid: 19019216].
2506 Stewart HJ. The Scottish trial of adjuvant tamoxifen in node-negative breast cancer. Scottish Cancer Trials Breast Group. J Natl Cancer Inst Monogr. 1992:117-20. Not eligible target population.
2507 Stierer M, Rosen HR, Weber R, et al. Long term analysis of factors influencing the outcome in carcinoma of the breast smaller than one centimeter. Surg Gynecol Obstet. Aug. 1992;175(2):151-60. Not eligible target populations. [pmid: 1321990].
2508 Stock RJ, Kunschner A, Mazer J, et al. Mammographic localization and biopsy: the experience of a gynecologic oncology group. Gynecol Oncol. May. 1989;33(2):172-6. Not eligible outcomes. [pmid: 2703176].
2509 Stockdale AD, Brierley JD, White WF, et al. Radiotherapy for Paget’s disease of the nipple: a conservative alternative. Lancet. Sep. 16. 1989;2(8664):664-6. Not eligible target population. [pmid: 2570909].
2510 Stockdale AD, Last P, Tucker AK, et al. Screening for breast cancer: some clinical aspects. Br J Surg. Jul. 1988;75(7):697-9. Not eligible oucomes. [pmid: 2843256].
2511 Stojadinovic A, Hooke JA, Shriver CD, et al. HYOU1/Orp150 expression in breast cancer. Med Sci Monit. Nov. 2007;13(11):BR231-9. Not eligible outcomes. [pmid: 17968289].
2512 Stokkel MP, Peterse HL. Angiosarcoma of the breast after lumpectomy and radiation therapy for adenocarcinoma. Cancer. Jun. 15. 1992;69(12):2965-8. Case Reports. [pmid: 1317249].
2513 Stolier AJ, Sullivan SK, Dellacroce FJ. Technical considerations in nipple-sparing mastectomy: 82 consecutive cases without necrosis. Ann Surg Oncol. May. 2008;15(5):1341-7. Not eligible outcomes. [pmid: 18256883].
2514 Stolier AJ, Wang J. Terminal duct lobular units are scarce in the nipple: implications for prophylactic nipple-sparing mastectomy: terminal duct lobular units in the nipple. Ann Surg Oncol. Feb. 2008;15(2):438-42. Not eligible target population. [pmid: 18004629].
2515 Stomper PC, Budnick RM, Stewart CC. Use of specimen mammography-guided FNA (fine-needle aspirates) for flow cytometric multiple marker analysis and immunophenotyping in breast cancer. Cytometry. Jun. 15. 2000;42(3):165-73. Not eligible outcomes. [pmid: 10861689].
2516 Stomper PC, Connolly JL. Ductal carcinoma in situ of the breast: correlation between mammographic calcification and tumor subtype. AJR Am J Roentgenol. Sep. 1992;159(3):483-5. Not eligible outcomes. [pmid: 1323923].
2517 Stomper PC, Connolly JL. Mammographic features predicting an extensive intraductal component in early-stage infiltrating ductal carcinoma. AJR Am J Roentgenol. Feb. 1992;158(2):269-72. Not eligible outcomes. [pmid: 1309620].
2518 Stomper PC, Connolly JL, Meyer JE, et al. Clinically occult ductal carcinoma in situ detected with mammography: analysis of 100 cases with radiologic-pathologic correlation. Radiology. Jul. 1989;172(1):235-41. Not eligible outcomes. [pmid: 2544922].
2519 Stomper PC, DeBloom JR 2nd, Winston JS, et al. Flow cytometric DNA analysis of specimen mammography-guided fine-needle aspirates of ductal carcinoma in situ. J Exp Clin Cancer Res. Sep. 2000;19(3):309-15. Not eligible outcomes. [pmid: 11144524].
2520 Stomper PC, Geradts J, Edge SB, et al. Mammographic predictors of the presence and size of invasive carcinomas associated with malignant microcalcification lesions without a mass. AJR Am J Roentgenol. Dec. 2003;181(6):1679-84. Not eligible outcomes. [pmid: 14627596].
2521 Stomper PC, Stewart CC, Penetrante RB, et al. Flow cytometric DNA analysis of excised breast lesions: use of fresh tissue needle aspirates obtained under guidance with mammography of the specimen. Radiology. Nov. 1992;185(2):415-22. Not eligible outcomes. [pmid: 1329141].
2522 Stonesifer GL Jr, Lowe RH, Cameron JL, et al. Conversion of hydrocortisone to estrogen in carcinoma of the breast after oophorectomy and adrenalectomy. Ann Surg. Nov. 1973;178(5):563-4. Not eligible outcomes. [pmid: 4355957].
2523 Storm FK, Gilchrist KW, Warner TF, et al. Distribution of Hsp-27 and HER-2/neu in in situ and invasive ductal breast carcinomas. Ann Surg Oncol. Jan. 1995;2(1):43-8. Not eligible outcomes. [pmid: 7530588].
2524 Stotter AT, McNeese M, Oswald MJ, et al. The role of limited surgery with irradiation in primary treatment of ductal in situ breast cancer. Int J Radiat Oncol Biol Phys. Feb. 1990;18(2):283-7. Not eligible level of evidence. [pmid: 2154417].
2525 Stranjalis G, Torrens MJ. Successful removal of intramedullary spinal cord metastasis: case report. Br J Neurosurg. 1993;7(2):193-5. Case Reports. [pmid: 8388221].
2526 Straver ME, van Adrichem JC, Rutgers EJ, et al. Neoadjuvant systemic therapy in patients with operable primary breast cancer: more benefits than breast-conserving therapy. Ned Tijdschr Geneeskd. Nov. 15. 2008;152(46):2519-25. Language. [pmid: 19055260].
2527 Strax P, Venet L, Shapiro S, et al. Breast cancer found on repetitive examination in mass screening. Arch Environ Health. Jun. 1970;20(6):758-63. Not eligible target population. [pmid: 4315318].
2528 Streckfus CF, Mayorga-Wark O, Arreola D, et al. Breast cancer related proteins are present in saliva and are modulated secondary to ductal carcinoma in situ of the breast. Cancer Invest. Mar. 2008;26(2):159-67. Not eligible outcomes. [pmid: 18259946].
2529 Stumpp J, Dietl J, Simon W, et al. Growth fraction in breast carcinoma determined by Ki-67 immunostaining: correlation with pathological and clinical variables. Gynecol Obstet Invest. 1992;33(1):47-50. Not eligible outcomes. [pmid: 1373397].
2530 Subramanian KR, Brockway JP, Carruthers WB. Interactive detection and visualization of breast lesions from dynamic contrast enhanced MRI volumes. Comput Med Imaging Graph. Dec. 2004;28(8):435-44. Case Reports. [pmid: 15541950].
2531 Suehiro S, Inai K, Tokuoka S, et al. Involvement of the nipple in early carcinoma of the breast. Surg Gynecol Obstet. Mar. 1989;168(3):244-8. Not eligible target population. [pmid: 2537537].
2532 Sugiyama M, Atomi Y. Intraductal papillary mucinous tumors of the pancreas: imaging studies and treatment strategies. Ann Surg. Nov. 1998;228(5):685-91. Not eligible target population. [pmid: 9833807].
2533 Sugiyama M, Atomi Y, Kuroda A. Two types of mucin-producing cystic tumors of the pancreas: diagnosis and treatment. Surgery. Sep. 1997;122(3):617-25. Not eligible target population. [pmid: 9308621].
2534 Suh WW, Hillner BE, Pierce LJ, et al. Cost-effectiveness of radiation therapy following conservative surgery for ductal carcinoma in situ of the breast. Int J Radiat Oncol Biol Phys. Mar. 15. 2005;61(4):1054-61. Cost-effectiveness analysis. [pmid: 15752884].
2535 Sukumvanich P, Bentrem DJ, Cody HS 3rd, et al. The role of sentinel lymph node biopsy in Paget’s disease of the breast. Ann Surg Oncol. Mar. 2007;14(3):1020-3. Not eligible target population. [pmid: 17195914].
2536 Sundararajan S, Tohno E, Kamma H, et al. Detection of intraductal component around invasive breast cancer using ultrasound: correlation with MRI and histopathological findings. Radiat Med. Feb. 2006;24(2):108-14. Not eligible target population. [pmid: 16715671].
2537 Suo Z, Bjaamer A, Ottestad L, et al. Expression of EGFR family and steroid hormone receptors in ductal carcinoma in situ of the breast. Ultrastruct Pathol. Sep–Oct. 2001;25(5):349-56. Not eligible outcomes. [pmid: 11758715].
2538 Suzuki N, Katsusihma H, Takeuchi K, et al. Cytogenetic abnormality 46,XX,add(21)(q11.2) in a patient with follicular dendritic cell sarcoma. Cancer Genet Cytogenet. Oct. 2008;186(1):54-7. Not eligible target population. [pmid: 18786443].
2539 Svitekova M, Minar L, Pacovsky Z. Breast cancer in puerperium. Klin Onkol. 2008;21(2):71-3. Language. [pmid: 19102215].
2540 Sydnor MK, Wilson JD, Hijaz TA, et al. Underestimation of the presence of breast carcinoma in papillary lesions initially diagnosed at core-needle biopsy. Radiology. Jan. 2007;242(1):58-62. Not eligible outcomes. [pmid: 17090707].
2541 Tada K, Nishimura S, Miyagi Y, et al. The effect of an old surgical scar on sentinel node mapping in patients with breast cancer: a report of five cases. Eur J Surg Oncol. Oct. 2005;31(8):840-4. Case Reports. [pmid: 16009528].
2542 Tada M, Omata M, Ohto M. Ras gene mutations in intraductal papillary neoplasms of the pancreas. Analysis in five cases. Cancer. Feb. 1. 1991;67(3):634-7. Not eligible target population. [pmid: 1845953].
2543 Tafra L, Fine R, Whitworth P, et al. Prospective randomized study comparing cryo-assisted and needle-wire localization of ultrasound-visible breast tumors. Am J Surg. Oct. 2006;192(4):462-70. Not eligible outcomes. [pmid: 16978950].
2544 Tafra L, Guenther JM, Giuliano AE. Planned segmentectomy. A necessity for breast carcinoma. Arch Surg. Sep. 1993;128(9):1014-8. discussion 8-20. Not eligible target population. [pmid: 8396387].
2545 Tahan SR, Neuberg DS, Dieffenbach A, et al. Prediction of early relapse and shortened survival in patients with breast cancer by proliferating cell nuclear antigen score. Cancer. Jun. 1. 1993;71(11):3552-9. Not eligible target population. [pmid: 8098267].
2546 Takahashi K, Makita M, Tada T, et al. Breast conserving treatment without radiotherapy. Biomed Pharmacother. 2002;56(Suppl 1):201s-4s. Not eligible target population. [pmid: 12487282].
2547 Takahashi K, Saito M, Makita M, et al. Surgery for ductal carcinoma in situ. Breast Cancer. 2000;7(4):337-40. Full text was not available. [pmid: 11114861].
2548 Takarabe T, Tsuda H, Okada S, et al. Detection of numerical alterations of chromosome 1 in cytopathological specimens of breast tumors by chromogen in situ hybridization. Pathol Int. Oct. 2001;51(10):786-91. Not eligible outcomes. [pmid: 11881731].
2549 Tamagawa E, Ueda M, Takahashi S, et al. Pancreatic lymph nodal and plexus micrometastases detected by enriched polymerase chain reaction and nonradioisotopic single-strand conformation polymorphism analysis: a new predictive factor for recurrent pancreatic carcinoma. Clin Cancer Res. Nov. 1997;3(11):2143-9. Not eligible target population. [pmid: 9815608].
2550 Tamaki K, Moriya T, Sato Y, et al. Vasohibin-1 in human breast carcinoma: a potential negative feedback regulator of angiogenesis. Cancer Sci. Jan. 2009;100(1):88-94. Not eligible outcomes. [pmid: 19037993].
2551 Tamimi RM, Baer HJ, Marotti J, et al. Comparison of molecular phenotypes of ductal carcinoma in situ and invasive breast cancer. Breast Cancer Res. 2008;10(4):R67. Not eligible outcomes. [pmid: 18681955].
2552 Tamiolakis D, Antoniou C. Axillary nodal metastasis of occult breast primary cancer. Chirurgia (Bucur). Jul–Aug. 2008;103(4):467-71. Case Reports. [pmid: 18780622].
2553 Tamiolakisl D, Venizelos I, Lambropoulou M, et al. Gains and losses of HLA class II (DR) and CD4 in atypical hyperplasia, carcinoma in situ and infiltrating ductal carcinoma of the breast. Acta Medica (Hradec Kralove). 2004;47(4):257-62. Not eligible outcomes. [pmid: 15844251].
2554 Tamura G, Maesawa C, Mikawa S, et al. Significance of immunohistochemically detected c-erbB-2 protein expression in stage III breast cancer, with reference to nuclear deformity, DNA content and prognosis. Jpn J Clin Oncol. Aug. 1991;21(4):264-7. Not eligible outcomes. [pmid: 1682519].
2555 Tamura G, Masuda T, Satoh T, et al. Karyometric and DNA content analyses of cancer cells in stage III breast cancer with reference to prognosis. Jpn J Clin Oncol. Mar. 1990;20(1):78-82. Not eligible target population. [pmid: 2157083].
2556 Tan EY, Campo L, Han C, et al. BNIP3 as a progression marker in primary human breast cancer; opposing functions in in situ versus invasive cancer. Clin Cancer Res. Jan. 15. 2007;13(2 Pt 1):467-74. Not eligible outcomes. [pmid: 17255267].
2557 Tan JE, Orel SG, Schnall MD, et al. Role of magnetic resonance imaging and magnetic resonance imaging--guided surgery in the evaluation of patients with early-stage breast cancer for breast conservation treatment. Am J Clin Oncol. Aug. 1999;22(4):414-8. Not eligible level of evidence. [pmid: 10440203].
2558 Tan KB, Lee HY, Putti TC. Ductal carcinoma in situ of the breast in Singapore: recent trends and clinical implications. ANZ J Surg. Nov. 2002;72(11):793-7. Not eligible outcomes. [pmid: 12437689].
2559 Tan KB, Yong WP, Putti TC. Cyclooxygenase-2 expression: a potential prognostic and predictive marker for high-grade ductal carcinoma in situ of the breast. Histopathology. Jan. 2004;44(1):24-8. Not eligible outcomes. [pmid: 14717665].
2560 Tan KY, Tan SM, Chiang SH, et al. Breast specimen ultrasound and mammography in the prediction of tumour-free margins. ANZ J Surg. Dec. 2006;76(12):1064-7. Not eligible outcomes. [pmid: 17199691].
2561 Tan MP. Surmounting the challenges of sentinel lymph node biopsy for breast cancer in non-tertiary centres and community-based practices. ANZ J Surg. May. 2006;76(5):306-9. Not eligible outcomes. [pmid: 16768687].
2562 Tan PH, Aw MY, Yip G, et al. Cytokeratins in papillary lesions of the breast: is there a role in distinguishing intraductal papilloma from papillary ductal carcinoma in situ. Am J Surg Pathol. May. 2005;29(5):625-32. Not eligible target population. [pmid: 15832086].
2563 Tan PH, Goh BB, Chiang G, et al. Correlation of nuclear morphometry with pathologic parameters in ductal carcinoma in situ of the breast. Mod Pathol. Oct. 2001;14(10):937-41. Not eligible outcomes. [pmid: 11598161].
2564 Tan PH, Ho JT, Ng EH, et al. Pathologic-radiologic correlations in screen-detected ductal carcinoma in situ of the breast: findings of the Singapore breast screening project. Int J Cancer. Aug. 20. 2000;90(4):231-6. Not eligible outcomes. [pmid: 10993963].
2565 Tan PH, Lui GG, Chiang G, et al. Ductal carcinoma in situ with spindle cells: a potential diagnostic pitfall in the evaluation of breast lesions. Histopathology. Oct. 2004;45(4):343-51. Not eligible outcomes. [pmid: 15469472].
2566 Tang P, Hajdu SI, Conte CC, et al. Incidental finding of mammary carcinoma in lumpectomy specimens. Ann Clin Lab Sci. Winter. 2003;33(1):23-31. Not eligible target population. [pmid: 12661895].
2567 Tang P, Wang X, Schiffhauer L, et al. Expression patterns of ER-alpha, PR, HER-2/neu, and EGFR in different cell origin subtypes of high grade and non-high grade ductal carcinoma in situ. Ann Clin Lab Sci. Spring. 2006;36(2):137-43. Not eligible outcomes. [pmid: 16682508].
2568 Tani EM, Skoog L. Immunocytochemical detection of estrogen receptors in mammary Paget cells. Acta Cytol. Nov–Dec. 1988;32(6):825-8. Not eligible target population. [pmid: 2849272].
2569 Tanigawa N, Kashihara S, Kuramoto S, et al. Paget’s disease of the breast. Nippon Geka Hokan. Sep. 1. 1974;43(5):390-4. Not eligible target population. [pmid: 4374145].
2570 Tanskanen M, Jahkola T, Asko-Seljavaara S, et al. HER2 oncogene amplification in extramammary Paget’s disease. Histopathology. Jun. 2003;42(6):575-9. Not eligible target population. [pmid: 12786893].
2571 Taourel P, Hoa D, Chaveron C, et al. Stereotactic vacuum biopsy of calcifications with a handheld portable biopsy system: a validation study. European radiology. Jul. 2008;18(7):1319-25. Not eligible exposure. [pmid: 18351352].
2572 Taplin SH, Rutter CM, Finder C, et al. Screening mammography: clinical image quality and the risk of interval breast cancer. AJR Am J Roentgenol. Apr. 2002;178(4):797-803. Not eligible outcomes. [pmid: 11906848].
2573 Taran A, Eggemann H, Costa SD, et al. Ovarian cyst torsion and extreme ovarian stimulation in a premenopausal patient treated with tamoxifen for ductal carcinoma in situ of the breast. Am J Obstet Gynecol. Oct. 2006;195(4):e5-6. Case Reports. [pmid: 17000228].
2574 Tartter PI, Bleiweiss IJ, Levchenko S. Factors associated with clear biopsy margins and clear reexcision margins in breast cancer specimens from candidates for breast conservation. J Am Coll Surg. Sep. 1997;185(3):268-73. Not eligible outcomes. [pmid: 9291405].
2575 Tashiro S, Uchino R, Hiraoka T, et al. Surgical indication and significance of portal vein resection in biliary and pancreatic cancer. Surgery. Apr. 1991;109(4):481-7. Not eligible target population. [pmid: 1848949].
2576 Tassin GB, Fornage BD, Sneige N. Primary multifocal angiosarcoma of the breast. Sonographic evaluation with pathologic correlation. J Ultrasound Med. Aug. 1990;9(8):481-3. Case Reports. [pmid: 2168955].
2577 Tate PS, Rogers EL, McGee EM, et al. Stereotactic breast biopsy: a six-year surgical experience. J Ky Med Assoc. Mar. 2001;99(3):98-103. Not eligible outcomes. [pmid: 11268786].
2578 Tavassoli FA. Breast pathology: rationale for adopting the ductal intraepithelial neoplasia (DIN) classification. Nat Clin Pract Oncol. Mar. 2005;2(3):116-7. Not eligible outcomes. [pmid: 16264885].
2579 Tavassoli FA, Norris HJ. Intraductal apocrine carcinoma: a clinicopathologic study of 37 cases. Mod Pathol. Oct. 1994;7(8):813-8. Not eligible target population. [pmid: 7838835].
2580 Taylor A, Cheng KK. Social deprivation and breast cancer. J Public Health Med. Sep. 2003;25(3):228-33. Not eligible outcomes. [pmid: 14575198].
2581 Tea MK, Asseryanis E, Kroiss R, et al. Surgical breast lesions in adolescent females. Pediatr Surg Int. Jan. 2009;25(1):73-5. Not eligible level of evidence. [pmid: 18985359].
2582 Teixeira MR, Pandis N, Bardi G, et al. Clonal heterogeneity in breast cancer: karyotypic comparisons of multiple intra- and extra-tumorous samples from 3 patients. Int J Cancer. Sep. 27. 1995;63(1):63-8. Case Reports. [pmid: 7558454].
2583 Teke Z, Kabay B, Akbulut M, et al. Primary infiltrating ductal carcinoma arising in aberrant breast tissue of the axilla: a rare entity. Report of a case. Tumori. Jul–Aug. 2008;94(4):577-83. Not eligible target population. [pmid: 18822697].
2584 Temple WJ. Surgical management of the patient at high risk for breast cancer. Can J Surg. May. 1985;28(3):256-7. 61. Comment. [pmid: 2986809].
2585 Teng-Swan Ho J, Tan PH, Hee SW, et al. Underestimation of malignancy of atypical ductal hyperplasia diagnosed on 11-gauge stereotactically guided Mammotome breast biopsy: an Asian breast screen experience. Breast. Aug. 2008;17(4):401-6. Not eligible exposure. [pmid: 18455920].
2586 Teo NB, Shoker BS, Jarvis C, et al. Angiogenesis and invasive recurrence in ductal carcinoma in situ of the breast. Eur J Cancer. Jan. 2003;39(1):38-44. Not eligible outcomes. [pmid: 12504656].
2587 Teo NB, Shoker BS, Jarvis C, et al. Thymidine phosphorylase expression and stromal vascularity in ductal carcinoma in situ of the breast. J Clin Pathol. Dec. 2003;56(12):919-23. Not eligible outcomes. [pmid: 14645350].
2588 Terashima M, Ogawa Y, Kariya S, et al. Breast-conservation treatment for patients with ductal carcinoma in situ. Oncol Rep. Nov–Dec. 2000;7(6):1247-52. No associative hypothesis tested. [pmid: 11032924].
2589 Tetu B, Brisson J, Cote C, et al. Prognostic significance of cathepsin-D expression in node-positive breast carcinoma: an immunohistochemical study. Int J Cancer. Sep. 30. 1993;55(3):429-35. Not eligible target population. [pmid: 8397164].
2590 Thai TH, Du F, Tsan JT, et al. Mutations in the BRCA1-associated RING domain (BARD1) gene in primary breast, ovarian and uterine cancers. Hum Mol Genet. Feb. 1998;7(2):195-202. Case Reports. [pmid: 9425226].
2591 Tham YL, Sexton K, Kramer R, et al. Primary breast cancer phenotypes associated with propensity for central nervous system metastases. Cancer. Aug. 15. 2006;107(4):696-704. Not eligible outcomes. [pmid: 16826579].
2592 Theodorakis SP, Tedesco VE 3rd, Sutherland CM. Breast cancer in a patient with prolactinoma. Surgery. Aug. 1985;98(2):367-9. Case Reports. [pmid: 2992109].
2593 Theriault RL, Buzdar AU. Acute superior vena caval thrombosis after central venous catheter removal: successful treatment with thrombolytic therapy. Med Pediatr Oncol. 1990;18(1):77-80. Case Reports. [pmid: 2152960].
2594 Theriault RL, Stallings CB, Buzdar AU. Pregnancy and breast cancer: clinical and legal issues. Am J Clin Oncol. Dec. 1992;15(6):535-9. Case Reports. [pmid: 1333169].
2595 Theve NO, Azavedo E, Blomstedt B, et al. The significance of quantitative biological cell parameters in the handling of mammary carcinoma. Acta Chir Scand. 1982;148(3):239-41. Case Reports. [pmid: 6291293].
2596 Thike AA, Chng MJ, Fook-Chong S, et al. Immunohistochemical expression of hormone receptors in invasive breast carcinoma: correlation of results of H-score with pathological parameters. Pathology. Feb. 2001;33(1):21-5. Not eligible outcomes. [pmid: 11280603].
2597 Thomas CJ, Wood GC, Marks VJ. Mohs micrographic surgery in the treatment of rare aggressive cutaneous tumors: the Geisinger experience. Dermatol Surg. Mar. 2007;33(3):333-9. Not eligible target population. [pmid: 17338692].
2598 Thomas J, Hanby A, Pinder S, et al. Implications of inconsistent measurement of ER status in non-invasive breast cancer: a study of 1,684 cases from the Sloane Project. Breast J. Jan–Feb. 2008;14(1):33-8. Not eligible outcomes. [pmid: 18186863].
2599 Thomas J, Hanby A, Pinder S, et al. Implications of inconsistent measurement of ER status in non-invasive breast cancer: a study of 1,684 cases from the Sloane Project. Breast Journal. Jan–Feb. 2008;14(1):33-8. Not eligible outcomes. [pmid: 18186863].
2600 Thomas P. A screened breast cancer. Br J Hosp Med. May. 1990;43(5):390-1. Case Reports. [pmid: 2163716].
2601 Thomas R, Godward S, Makris A, et al. Giving patients a choice improves quality of life: a multi-centre, investigator-blind, randomised, crossover study comparing letrozole with anastrozole. Clin Oncol (R Coll Radiol). Oct. 2004;16(7):485-91. Not eligible target population. [pmid: 15490811].
2602 Thomassen M, Kruse TA, Olsen KE, et al. Loss of heterozygosity at BRCA2 in a ductal carcinoma in situ and three invasive breast carcinomas in a family with a germline BRCA2 mutation. Breast Cancer Res Treat. Oct. 2004;87(3):273-6. Case Reports. [pmid: 15528970].
2603 Thompson TA, Pusic A, Kerrigan CL, et al. Surgeon perspectives on surgical options for early-stage breast cancer. Plast Reconstr Surg. Mar. 2000;105(3):910-8. Not eligible outcomes. [pmid: 10724250].
2604 Thompson WR, Bowen JR, Dorman BA, et al. Mammographic localization and biopsy of nonpalpable breast lesions. A 5-year study. Arch Surg. Jun. 1991;126(6):730-3. discussion 3-4. Not eligible outcomes. [pmid: 1645516].
2605 Thor AD, Moore DH II, Edgerton SM, et al. Accumulation of p53 tumor suppressor gene protein: an independent marker of prognosis in breast cancers. J Natl Cancer Inst. Jun. 3. 1992;84(11):845-55. Not eligible outcomes. [pmid: 1317462].
2606 Thornton HM. Breast cancer trials: a patient’s viewpoint. Lancet. Jan. 4. 1992;339(8784):44-5. Comment. [pmid: 1345963].
2607 Thurfjell MG, Lindgren A, Thurfjell E. Nonpalpable breast cancer: mammographic appearance as predictor of histologic type. Radiology. Jan. 2002;222(1):165-70. Not eligible outcomes. [pmid: 11756721].
2608 Thurlimann B, Castiglione M, Hsu-Schmitz SF, et al. Formestane versus megestrol acetate in postmenopausal breast cancer patients after failure of tamoxifen: a phase III prospective randomised cross over trial of second-line hormonal treatment (SAKK 20/90). Swiss Group for Clinical Cancer Research (SAKK). Eur J Cancer. Jun. 1997;33(7):1017-24. Not eligible target population. [pmid: 9376181].
2609 Thurlimann B, Hess D, Koberle D, et al. Anastrozole (‘Arimidex’) versus tamoxifen as first-line therapy in postmenopausal women with advanced breast cancer: results of the double-blind cross-over SAKK trial 21/95--a sub-study of the TARGET (Tamoxifen or ‘Arimidex’ Randomized Group Efficacy and Tolerability) trial. Breast Cancer Res Treat. Jun. 2004;85(3):247-54. Not eligible target population. [pmid: 15111763].
2610 Thurlimann B, Keshaviah A, Coates AS, et al. A comparison of letrozole and tamoxifen in postmenopausal women with early breast cancer. N Engl J Med. Dec. 29. 2005;353(26):2747-57. Not eligible target population. [pmid: 16382061].
2611 Tianco EA, Medina-Lavadia AT, Atienza NL, et al. Multiple cutaneous metastases from breast carcinoma. Cutis. Mar. 1990;45(3):171-5. Case Reports. [pmid: 2155759].
2612 Tibiletti MG, Sessa F, Bernasconi B, et al. A large 6q deletion is a common cytogenetic alteration in fibroadenomas, pre-malignant lesions, and carcinomas of the breast. Clin Cancer Res. Apr. 2000;6(4):1422-31. Not eligible outcomes. [pmid: 10778973].
2613 Tilakaratna AD, Rodrigo T, de Silva MV. Extensive intraduct component in invasive duct carcinoma of the breast: prevalence and significance in a south Asian setting. Indian J Cancer. Mar. 2000;37(1):1-3. Not eligible target population. [pmid: 11261229].
2614 Tilanus-Linthorst M, Verhoog L, Obdeijn IM, et al. A BRCA1/2 mutation, high breast density and prominent pushing margins of a tumor independently contribute to a frequent false-negative mammography. Int J Cancer. Nov. 1. 2002;102(1):91-5. Not eligible outcomes. [pmid: 12353239].
2615 Tiling R, Khalkhali I, Sommer H, et al. Limited value of scintimammography and contrast-enhanced MRI in the evaluation of microcalcification detected by mammography. Nucl Med Commun. Jan. 1998;19(1):55-62. Not eligible level of evidence. [pmid: 9515547].
2616 Tinnemans JG, Wobbes T, Holland R, et al. Mammographic and histopathologic correlation of nonpalpable lesions of the breast and the reliability of frozen section diagnosis. Surg Gynecol Obstet. Dec. 1987;165(6):523-9. Not eligible outcomes. [pmid: 2825366].
2617 Toennissen J, Schrudde J, Niermann W. Experience with 250 cases of subcutaneous mastectomy. Br J Plast Surg. Oct. 1982;35(4):458-65. Not eligible target population. [pmid: 7139173].
2618 Tohno E, Ueno E. Current improvements in breast ultrasound, with a special focus on elastography. Breast Cancer. 2008;15(3):200-4. Not eligible exposure. [pmid: 18484155].
2619 Toker C. Small-cell dysplasia and in situ carcinoma of the breast: incidence and age distribution in patients biopsied over a 29-year period. Mt Sinai J Med. May–Jun. 1976;43(3):226-31. Not eligible target population. [pmid: 1084466].
2620 Tokes AM, Kulka J, Paku S, et al. Claudin-1, −3 and −4 proteins and mRNA expression in benign and malignant breast lesions: a research study. Breast Cancer Res. 2005;7(2):R296-305. Not eligible outcomes. [pmid: 15743508].
2621 Tokes AM, Paku S, Toth S, et al. Tenascin expression in primary and recurrent breast carcinomas and the effect of tenascin on breast tumor cell cultures. Pathol Oncol Res. 2000;6(3):202-9. Not eligible target population. [pmid: 11033461].
2622 Tolmos J, Cutrone JA, Wang B, et al. Scintimammographic analysis of nonpalpable breast lesions previously identified by conventional mammography. J Natl Cancer Inst. Jun. 3. 1998;90(11):846-9. Not eligible outcomes. [pmid: 9625173].
2623 Tomaszewska R, Nowak K, Stachura J. CD44 isoforms expression in intraductal and invasive pancreatic cancer and its correlation to p53 gene mutations. Pol J Pathol. 1999;50(3):145-53. Not eligible target population. [pmid: 10624116].
2624 Tominaga T, Adachi I, Sasaki Y, et al. Double-blind randomised trial comparing the non-steroidal aromatase inhibitors letrozole and fadrozole in postmenopausal women with advanced breast cancer. Ann Oncol. Jan. 2003;14(1):62-70. Not eligible target population. [pmid: 12488294].
2625 Tommiska J, Eerola H, Heinonen M, et al. Breast cancer patients with p53 Pro72 homozygous genotype have a poorer survival. Clin Cancer Res. Jul. 15. 2005;11(14):5098-103. Not eligible target population. [pmid: 16033823].
2626 Tonegutti M, Girardi V. Stereotactic vacuum-assisted breast biopsy in 268 nonpalpable lesions. Radiol Med (Torino). Feb. 2008;113(1):65-75. Not eligible outcomes. [pmid: 18338128].
2627 Torres L, Ribeiro FR, Pandis N, et al. Intratumor genomic heterogeneity in breast cancer with clonal divergence between primary carcinomas and lymph node metastases. Breast Cancer Res Treat. Apr. 2007;102(2):143-55. Not eligible outcomes. [pmid: 16906480].
2628 Tosios K, Vasilas A, Arsenopoulos A. Metastatic breast carcinoma of the masseter: case report. J Oral Maxillofac Surg. Mar. 1992;50(3):304-6. Case Reports. [pmid: 1371808].
2629 Toth BA, Daane SP. Purse-string mastectomy with immediate prosthetic reconstruction: an improved skin-sparing technique for small breasts. Plast Reconstr Surg. Jun. 2003;111(7):2333-7. Case Reports. [pmid: 12794477].
2630 Toth BA, Lappert P. Modified skin incisions for mastectomy: the need for plastic surgical input in preoperative planning. Plast Reconstr Surg. Jun. 1991;87(6):1048-53. Case Reports. [pmid: 1852020].
2631 Toya H, Oyama T, Ohwada S, et al. Immunohistochemical expression of the beta-catenin-interacting protein references.r9L is associated with histological high nuclear grade and immunohistochemical ErbB2/HER-2 expression in breast cancers. Cancer Sci. Apr. 2007;98(4):484-90. Not eligible outcomes. [pmid: 17309600].
2632 Tozaki M, Kawakami M, Suzuki M, et al. Diagnosis of Tis/T1 breast cancer extent by multislice helical CT: a novel classification of tumor distribution. Radiat Med. Sep–Oct. 2003;21(5):187-92. Not eligible outcomes. [pmid: 14632293].
2633 Tozaki M, Uno S, Kobayashi T, et al. Histologic breast cancer extent after neoadjuvant chemotherapy: comparison with multidetector-row CT and dynamic MRI. Radiat Med. Jul–Aug. 2004;22(4):246-53. Not eligible target population. [pmid: 15468945].
2634 Tozaki M, Yamashiro N, Suzuki T, et al. MR-guided vacuum-assisted breast biopsy: is it an essential technique. Breast Cancer. 2008. Sep. 20. Not eligible exposure.
2635 Tran DD, Lawson JS. Microcysts and breast cancer: a study of biological markers in archival biopsy material. Breast Cancer Res Treat. Oct. 2002;75(3):213-20. Not eligible outcomes. [pmid: 12353810].
2636 Trattner A, Figer A, David M, et al. Circumscribed scleroderma induced by postlumpectomy radiation therapy. Cancer. Nov. 15. 1991;68(10):2131-3. Case Reports. [pmid: 1655201].
2637 Tremblay G, Deschenes J, Alpert L, et al. Overexpression of estrogen receptors in columnar cell change and in unfolding breast lobules. Breast J. Sep–Oct. 2005;11(5):326-32. Not eligible target population. [pmid: 16174153].
2638 Tresserra F, Feu J, Grases PJ, et al. Assessment of breast cancer size: sonographic and pathologic correlation. J Clin Ultrasound. Nov–Dec. 1999;27(9):485-91. Not eligible target population. [pmid: 10525209].
2639 Tresserra F, Grases PJ, Fabregas R, et al. Paget’s disease of mammary skin without nipple involvement. A report of three cases. Eur J Gynaecol Oncol. 1999;20(4):283-4. Case Reports. [pmid: 10475124].
2640 Trimis G, Chatzistamou I, Politi K, et al. Expression of p21waf1/Cip1 in stromal fibroblasts of primary breast tumors. Hum Mol Genet. Nov. 15. 2008;17(22):3596-600. Not eligible outcomes. [pmid: 18713757].
2641 Trombetta M, Julian T, Bhandari T, et al. Breast conservation surgery and interstitial brachytherapy in the management of locally recurrent carcinoma of the breast: the Allegheny General Hospital experience. Brachytherapy. Jan–Mar. 2008;7(1):29-36. Not eligible target population. [pmid: 18201940].
2642 Trombetta M, Julian T, Miften M, et al. The use of the MammoSite balloon applicator in re-irradiation of the breast. Brachytherapy. Oct–Dec. 2008;7(4):316-9. Not eligible target population. [pmid: 18786865].
2643 Truong K, Guilly MN, Gerbault-Seureau M, et al. Evidence for in vitro selection during cell culturing of breast cancer: detection by flow and image cytometry. Cancer Genet Cytogenet. Oct. 15. 1999;114(2):154-5. Not eligible outcomes. [pmid: 10549274].
2644 Truong K, Vielh P, Guilly MN, et al. Quantitative FISH analysis on interphase nuclei may improve diagnosis of DNA diploid breast cancers. Diagn Cytopathol. Apr. 2002;26(4):213-6. Not eligible outcomes. [pmid: 11933265].
2645 Tsai KB, Hou MF, Lin HJ, et al. Expression of HER-2/NEU oncoprotein in familial and non-familial breast cancer. Kaohsiung J Med Sci. Feb. 2001;17(2):64-76. Not eligible outcomes. [pmid: 11416960].
2646 Tsai WC, Chu CH, Yu CP, et al. Matriptase and survivin expression associated with tumor progression and malignant potential in breast cancer of Chinese women: tissue microarray analysis of immunostaining scores with clinicopathological parameters. Dis Markers. 2008;24(2):89-99. Not eligible outcomes. [pmid: 18219094].
2647 Tsang WY, Chan JK. Neural invasion in intraductal carcinoma of the breast. Hum Pathol. Feb. 1992;23(2):202-4. Case Reports. [pmid: 1310953].
2648 Tsang WY, Chan JK. Endocrine ductal carcinoma in situ (E-DCIS) of the breast: a form of low-grade DCIS with distinctive clinicopathologic and biologic characteristics. Am J Surg Pathol. Aug. 1996;20(8):921-43. Not eligible target population. [pmid: 8712293].
2649 Tse GM, Cheung HS, Pang LM, et al. Characterization of lesions of the breast with proton MR spectroscopy: comparison of carcinomas, benign lesions, and phyllodes tumors. AJR Am J Roentgenol. Nov. 2003;181(5):1267-72. Not eligible outcomes. [pmid: 14573418].
2650 Tse GM, Law BK, Ma TK, et al. Hamartoma of the breast: a clinicopathological review. J Clin Pathol. Dec. 2002;55(12):951-4. Not eligible outcomes. [pmid: 12461066].
2651 Tse GM, Law BK, Pang LM, et al. Ductal carcinoma in situ arising in mammary hamartoma. J Clin Pathol. Jul. 2002;55(7):541-2. Case Reports. [pmid: 12101205].
2652 Tse GM, Ma TK. Fine-needle aspiration cytology of breast carcinoma with endocrine differentiation. Cancer. Oct. 25. 2000;90(5):286-91. Case Reports. [pmid: 11038425].
2653 Tse GM, Ma TK, Chu WC, et al. Neuroendocrine differentiation in pure type mammary mucinous carcinoma is associated with favorable histologic and immunohistochemical parameters. Mod Pathol. May. 2004;17(5):568-72. Not eligible target population. [pmid: 15001999].
2654 Tse GM, Somali A, Chan AW, et al. Fine needle aspiration cytology of breast cancer in women aged 70 years and older. Pathology. Oct. 2008;40(6):573-9. Not eligible outcomes. [pmid: 18752123].
2655 Tsuboi N, Ogawa Y, Inomata T, et al. Changes in the findings of dynamic MRI by preoperative CAF chemotherapy for patients with breast cancer of stage II and III: pathologic correlation. Oncol Rep. Jul–Aug. 1999;6(4):727-32. Not eligible target population. [pmid: 10373646].
2656 Tsuchiya S, Takayama S, Higashi Y. Electron microscopy of intraductal papilloma of the breast. Ultrastructural comparison of papillary carcinoma with normal mammary large duct. Acta Pathol Jpn. Jan. 1983;33(1):97-112. Not eligible outcomes. [pmid: 6301211].
2657 Tsuda H, Fukutomi T, Hirohashi S. Pattern of gene alterations in intraductal breast neoplasms associated with histological type and grade. Clin Cancer Res. Mar. 1995;1(3):261-7. Not eligible outcomes. [pmid: 9815981].
2658 Tsuda H, Hirohashi S. Multiple developmental pathways of highly aggressive breast cancers disclosed by comparison of histological grades and c-erbB-2 expression patterns in both the non-invasive and invasive portions. Pathol Int. Jul. 1998;48(7):518-25. Not eligible outcomes. [pmid: 9701014].
2659 Tsuda H, Hirohashi S, Shimosato Y, et al. Correlation between histologic grade of malignancy and copy number of c-erbB-2 gene in breast carcinoma. A retrospective analysis of 176 cases. Cancer. Apr. 15. 1990;65(8):1794-800. Not eligible outcomes. [pmid: 2156604].
2660 Tsuda H, Iwaya K, Fukutomi T, et al. p53 mutations and c-erbB-2 amplification in intraductal and invasive breast carcinomas of high histologic grade. Jpn J Cancer Res. Apr. 1993;84(4):394-401. Not eligible outcomes. [pmid: 8099903].
2661 Tsuda H, Takarabe T, Hirohashi S. Correlation of numerical and structural status of chromosome 16 with histological type and grade of non-invasive and invasive breast carcinomas. Int J Cancer. Aug. 20. 1999;84(4):381-7. Not eligible outcomes. [pmid: 10404090].
2662 Tsuda H, Takarabe T, Susumu N, et al. Detection of numerical and structural alterations and fusion of chromosomes 16 and 1 in low-grade papillary breast carcinoma by fluorescence in situ hybridization. Am J Pathol. Oct. 1997;151(4):1027-34. Not eligible outcomes. [pmid: 9327736].
2663 Tsugawa K, Noguchi M, Miwa K, et al. Dye- and gamma probe-guided sentinel lymph node biopsy in breast cancer patients: using patent blue dye and technetium-99m-labeled human serum albumin. Breast Cancer. Jan. 2000;7(1):87-94. Not eligible outcomes. [pmid: 11029778].
2664 Tsukamoto K, Yoshimoto M, Kasumi F, et al. Frequent multiplication of chromosome 1q in non-invasive and papillotubular carcinoma of the breast. Cancer Lett. Jul. 1. 1. 1999:141-2. 21. 8. Not eligible outcomes.
2665 Tsurudome Y, Katsuki T, Konishi T, et al. A case of low grade ductal carcinoma in situ of the breast with difficulties in making the preoperative diagnosis after detection by FDG-PET. J UOEH. Sep. 1. 2008;30(3):321-8. Language. [pmid: 18783013].
2666 Tubiana-Hulin M, Le Doussal V, Hacene K, et al. Sequential identification of factors predicting distant relapse in breast cancer patients treated by conservative surgery. Cancer. Aug. 15. 1993;72(4):1261-71. Not eligible target population. [pmid: 8393370].
2667 Tuccari G, Rizzo A, Barresi G. Immunocytochemical demonstration of calmodulin and its activated forms in normal and carcinomatous human mammary tissue. Eur J Histochem. 1993;37(1):59-64. Not eligible outcomes. [pmid: 7682869].
2668 Tweedie E, Tonkin K, Kerkvliet N, et al. Biologic characteristics of breast cancer detected by mammography and by palpation in a screening program: a pilot study. Clin Invest Med. Oct. 1997;20(5):300-7. Not eligible outcomes. [pmid: 9336655].
2669 Tyler JR, Baird L, Jones T, et al. Cytology: a useful adjunct in the management of nipple discharge. Aust N Z J Surg. Dec. 1982;52(6):610-2. Case Reports. [pmid: 6299262].
2670 Ueda S, Tsuda H, Asakawa H, et al. Clinicopathological and prognostic relevance of uptake level using 18F-fluorodeoxyglucose positron emission tomography/computed tomography fusion imaging (18F-FDG PET/CT) in primary breast cancer. Japanese journal of clinical oncology. Apr. 2008;38(4):250-8. Not eligible outcomes. [pmid: 18407934].
2671 Uematsu T, Kasami M. Soft-copy reading in digital mammography of mass: diagnostic performance of a 5-megapixel cathode ray tube monitor versus a 3-megapixel liquid crystal display monitor in a diagnostic setting. Acta radiologica. Jul. 2008;49(6):623-9. Not eligible exposure. [pmid: 18568553].
2672 Uematsu T, Kasami M, Yuen S. Usefulness and limitations of the Japan Mammography Guidelines for the categorization of microcalcifications. Breast Cancer. 2008;15(4):291-7. Not eligible outcomes. [pmid: 18288569].
2673 Uematsu T, Sano M, Homma K, et al. Comparison between high-resolution helical CT and pathology in breast examination. Acta Radiol. Jul. 2002;43(4):385-90. Not eligible target population. [pmid: 12225480].
2674 Uematsu T, Sano M, Homma K, et al. Value of Three-Dimensional Helical CT Image-Guided Planning for Made-to-Order Lumpectomy in Breast Cancer Patients. Breast J. Jan–Feb. 2004;10(1):33-7. Not eligible outcomes. [pmid: 14717757].
2675 Uematsu T, Sano M, Homma K, et al. Three-dimensional helical CT of the breast: accuracy for measuring extent of breast cancer candidates for breast conserving surgery. Breast Cancer Res Treat. Feb. 2001;65(3):249-57. Not eligible outcomes. [pmid: 11336247].
2676 Ugolini F, Charafe-Jauffret E, Bardou VJ, et al. WNT pathway and mammary carcinogenesis: loss of expression of candidate tumor suppressor gene SFRP1 in most invasive carcinomas except of the medullary type. Oncogene. Sep. 13. 2001;20(41):5810-7. Not eligible outcomes. [pmid: 11593386].
2677 Ulivi P, Zoli W, Medri L, et al. c-kit and SCF expression in normal and tumor breast tissue. Breast Cancer Res Treat. Jan. 2004;83(1):33-42. Not eligible outcomes. [pmid: 14997053].
2678 Umbricht CB, Evron E, Gabrielson E, et al. Hypermethylation of 14-3-3 sigma (stratifin) is an early event in breast cancer. Oncogene. Jun. 7. 2001;20(26):3348-53. Not eligible outcomes. [pmid: 11423985].
2679 Umbricht CB, Sherman ME, Dome J, et al. Telomerase activity in ductal carcinoma in situ and invasive breast cancer. Oncogene. Jun. 3. 1999;18(22):3407-14. Not eligible outcomes. [pmid: 10362362].
2680 Umekita Y, Ohi Y, Sagara Y, et al. Expression of maspin predicts poor prognosis in breast-cancer patients. Int J Cancer. Aug. 1. 2002;100(4):452-5. Not eligible outcomes. [pmid: 12115529].
2681 Umemura S, Yoshida S, Ohta Y, et al. Increased phosphorylation of Akt in triple-negative breast cancers. Cancer Sci. Dec. 2007;98(12):1889-92. Not eligible outcomes. [pmid: 17892507].
2682 Umpleby HC, Herbert A, Royle GT, et al. Wide excision of primary breast cancer: the incidence of residual carcinoma at the site of excision. Ann R Coll Surg Engl. Jul. 1988;70(4):246-8. Not eligible outcomes. [pmid: 2843075].
2683 Underwood LJ, Green WS. Carcinoma of areola and nipple of the breast: Paget’s disease versus carcinoma in situ. Arch Dermatol. Apr. 1965;91(4):407-8. Not eligible target population.
2684 Unek IT, Alacacioglu A, Tarhan O, et al. Synchronous appearance of male breast cancer and pancreatic cancer 15 years after the diagnosis of testicular cancer--report of a case. J BUON. Jul–Sep. 2008;13(3):421-4. Case Reports. [pmid: 18979560].
2685 Urabe A, Matsukuma A, Shimizu N, et al. Extramammary Paget’s disease: comparative histopathologic studies of intraductal carcinoma of the breast and apocrine adenocarcinoma. J Cutan Pathol. Oct. 1990;17(5):257-65. Not eligible target population. [pmid: 2175320].
2686 Utada Y, Haga S, Kajiwara T, et al. Mapping of target regions of allelic loss in primary breast cancers to 1-cM intervals on genomic contigs at 6q21 and 6q25.3. Jpn J Cancer Res. Mar. 2000;91(3):293-300. Not eligible outcomes. [pmid: 10760688].
2687 Vachon CM, Ingle JN, Suman VJ, et al. Pilot study of the impact of letrozole vs. placebo on breast density in women completing 5 years of tamoxifen. Breast. Apr. 2007;16(2):204-10. Not eligible target population. [pmid: 17145182].
2688 Vag T, Baltzer PA, Renz DM, et al. Diagnosis of ductal carcinoma in situ using contrast-enhanced magnetic resonance mammography compared with conventional mammography. Clin Imaging. Nov–Dec. 2008;32(6):438-42. Not eligible outcomes. [pmid: 19006771].
2689 Vaideeswar P, Madiwale C, Sivaraman A. Carcinoma arising within fibroadenoma--a case report. Indian J Pathol Microbiol. Jan. 2000;43(1):87-9. Case Reports. [pmid: 12583428].
2690 Valle M, Di Salle E, Jannuzzo MG, et al. A predictive model for exemestane pharmacokinetics/pharmacodynamics incorporating the effect of food and formulation. Br J Clin Pharmacol. Mar. 2005;59(3):355-64. Not eligible outcomes. [pmid: 15752382].
2691 van de Vijver MJ, Peterse JL, Mooi WJ, et al. Neu-protein overexpression in breast cancer. Association with comedo-type ductal carcinoma in situ and limited prognostic value in stage II breast cancer. N Engl J Med. Nov. 10. 1988;319(19):1239-45. Not eligible outcomes. [pmid: 2903446].
2692 van der Flier S, van der Kwast TH, Claassen CJ, et al. Immunohistochemical study of the BCAR1/p130Cas protein in non-malignant and malignant human breast tissue. Int J Biol Markers. Jul–Sep. 2001;16(3):172-8. Not eligible outcomes. [pmid: 11605729].
2693 van der Gaast A, Alexieva-Figusch J, Vecht C, et al. Complete remission of a brain metastasis to third-line hormonal treatment with megestrol acetate. Am J Clin Oncol. Dec. 1990;13(6):507-9. Case Reports. [pmid: 2173393].
2694 van der Putte SC, Toonstra J, Hennipman A. Mammary Paget’s disease confined to the areola and associated with multifocal Toker cell hyperplasia. Am J Dermatopathol. Oct. 1995;17(5):487-93. Not eligible target population. [pmid: 8599455].
2695 van der Wall E, Richel DJ, Kusumanto YH, et al. Feasibility study of FEC-chemotherapy with dose-intensive epirubicin as initial treatment in high-risk breast cancer. Ann Oncol. Nov. 1993;4(9):791-2. Not eligible target population. [pmid: 8280661].
2696 van der Wall E, Rutgers EJ, Holtkamp MJ, et al. Efficacy of up-front 5-fluorouracil-epidoxorubicin-cyclophosphamide (FEC) chemotherapy with an increased dose of epidoxorubicin in high-risk breast cancer patients. Br J Cancer. May. 1996;73(9):1080-5. Not eligible target population. [pmid: 8624267].
2697 van Deurzen CH, de Boer M, Monninkhof EM, et al. Non-sentinel lymph node metastases associated with isolated breast cancer cells in the sentinel node. J Natl Cancer Inst. Nov. 19. 2008;100(22):1574-80. Not eligible target population. [pmid: 19001602].
2698 Van Esser S, Hobbelink M, Van der Ploeg IM, et al. Radio guided occult lesion localization (ROLL) for non-palpable invasive breast cancer. J Surg Oncol. Dec. 1. 2008;98(7):526-9. Not eligible target population. [pmid: 18767074].
2699 van Gestel YR, Voogd AC, Vingerhoets AJ, et al. A comparison of quality of life, disease impact and risk perception in women with invasive breast cancer and ductal carcinoma in situ. Eur J Cancer. Feb. 2007;43(3):549-56. Not eligible level of evidence. [pmid: 17140788].
2700 Van Goethem M, Schelfout K, Kersschot E, et al. MR mammography is useful in the preoperative locoregional staging of breast carcinomas with extensive intraductal component. Eur J Radiol. May. 2007;62(2):273-82. Not eligible outcomes. [pmid: 17223002].
2701 Van Goethem M, Schelfout K, Kersschot E, et al. Enhancing area surrounding breast carcinoma on MR mammography: comparison with pathological examination. Eur Radiol. Aug. 2004;14(8):1363-70. Not eligible outcomes. [pmid: 15045522].
2702 Van Goethem M, Schelfout K, Kersschot E, et al. Comparison of MRI features of different grades of DCIS and invasive carcinoma of the breast. JBR-BTR. Sep–Oct. 2005;88(5):225-32. Full text was not available. [pmid: 16302331].
2703 Van Hoef ME, Knox WF, Dhesi SS, et al. Assessment of tumour vascularity as a prognostic factor in lymph node negative invasive breast cancer. Eur J Cancer. 1993;29A(8):1141-5. Not eligible outcomes. [pmid: 8390846].
2704 Van Limbergen E, Van der Schueren E, Van den Bogaert W, et al. Local control of operable breast cancer after radiotherapy alone. Eur J Cancer. 1990;26(6):674-9. Not eligible level of evidence. [pmid: 2168190].
2705 van Wely BJ, Smidt ML, de Kievit IM, et al. False-negative sentinel lymph node biopsy. Br J Surg. Nov. 2008;95(11):1352-5. Not eligible target population. [pmid: 18844270].
2706 Vandeweyer E. Peri-areolar skin-sparing mastectomy and immediate tram flap reconstruction. Acta Chir Belg. Apr. 2003;103(2):219-24. Not eligible target population. [pmid: 12768868].
2707 Vandeweyer E, Hertens D. Quantification of glands and fat in breast tissue: an experimental determination. Ann Anat. Mar. 2002;184(2):181-4. Not eligible outcomes. [pmid: 11936199].
2708 Vanek N, Hortobagyi GN, Buzdar AU. Radiotherapy enhances the toxicity of aminoglutethimide. Med Pediatr Oncol. 1990;18(2):162-4. Case Reports. [pmid: 2154663].
2709 Varga Z, Caduff R. Glycogen-rich carcinomas of the breast display unique characteristics with respect to proliferation and the frequency of oligonucleosomal fragments. Breast Cancer Res Treat. Sep. 1999;57(2):215-9. Not eligible target population. [pmid: 10598049].
2710 Vargas HI, Agbunag RV, Kalinowski A, et al. The clinical utility of Tc-99m sestamibi scintimammography in detecting multicentric breast cancer. Am Surg. Dec. 2001;67(12):1204-8. Not eligible outcomes. [pmid: 11768831].
2711 Vargas J, Nevado M, Rodriguez-Peralto JL, et al. Fine needle aspiration diagnosis of carcinoma arising in an ectopic breast. A case report. Acta Cytol. Sep–Oct. 1995;39(5):941-4. Case Reports. [pmid: 7571974].
2712 Vaughan A, Dietz JR, Aft R, et al. Scientific Presentation Award. Patterns of local breast cancer recurrence after skin-sparing mastectomy and immediate breast reconstruction. Am J Surg. Oct. 2007;194(4):438-43. Not eligible target population. [pmid: 17826052].
2713 Vauthey JN, Sclafani LM. Breast carcinoma presenting as chondrosternal thickening: a long-standing masquerade. Surgery. May. 1993;113(5):587-9. Case Reports. [pmid: 8387699].
2714 Velicer CM, Taplin S. Genetic testing for breast cancer: where are health care providers in the decision process. Genet Med. Mar–Apr. 2001;3(2):112-9. Not eligible target population. [pmid: 11280948].
2715 Venegas R, Rutgers JL, Cameron BL, et al. Fine needle aspiration cytology of breast ductal carcinoma in situ. Acta Cytol. Mar–Apr. 1994;38(2):136-43. Not eligible outcomes. [pmid: 8147202].
2716 Venta LA, Kim JP, Pelloski CE, et al. Management of complex breast cysts. AJR Am J Roentgenol. Nov. 1999;173(5):1331-6. Not eligible outcomes. [pmid: 10541113].
2717 Vergote I, Robertson JF, Kleeberg U, et al. Postmenopausal women who progress on fulvestrant (‘Faslodex’) remain sensitive to further endocrine therapy. Breast Cancer Res Treat. May. 2003;79(2):207-11. Not eligible target population. [pmid: 12825855].
2718 Verkooijen HM. Diagnostic accuracy of stereotactic large-core needle biopsy for nonpalpable breast disease: results of a multicenter prospective study with 95% surgical confirmation. Int J Cancer. Jun. 20. 2002;99(6):853-9. Not eligible outcomes. [pmid: 12115488].
2719 Verkooijen HM, Fioretta G, De Wolf C, et al. Management of women with ductal carcinoma in situ of the breast: a population-based study. Ann Oncol. Aug. 2002;13(8):1236-45. Not eligible outcomes. [pmid: 12181247].
2720 Verlinden I, Janssens J, Raus J, et al. Microdissection and SAGE as a combined tool to reveal gene expression in ductal carcinoma in situ of the breast. Mol Carcinog. Dec. 2004;41(4):197-206. Not eligible outcomes. [pmid: 15486950].
2721 Veronesi U, Cascinelli N, Greco M, et al. Prognosis of breast cancer patients after mastectomy and dissection of internal mammary nodes. Ann Surg. Dec. 1985;202(6):702-7. Not eligible target population. [pmid: 3000303].
2722 Veronesi U, De Palo G, Marubini E, et al. Randomized trial of fenretinide to prevent second breast malignancy in women with early breast cancer. J Natl Cancer Inst. Nov. 3. 1999;91(21):1847-56. Not eligible target population. [pmid: 10547391].
2723 Veronesi U, Luini A, Del Vecchio M, et al. Radiotherapy after breast-preserving surgery in women with localized cancer of the breast. N Engl J Med. Jun. 3. 1993;328(22):1587-91. Not eligible target population. [pmid: 8387637].
2724 Vestey SB, Perks CM, Sen C, et al. Immunohistochemical expression of insulin-like growth factor binding protein-3 in invasive breast cancers and ductal carcinoma in situ: implications for clinicopathology and patient outcome. Breast Cancer Res. 2005;7(1):R119-29. Not eligible outcomes. [pmid: 15642160].
2725 Viacava P, Naccarato AG, Bevilacqua G. Different proliferative patterns characterize different preinvasive breast lesions. J Pathol. Jul. 1999;188(3):245-51. Not eligible outcomes. [pmid: 10419590].
2726 Viacava P, Naccarato AG, Bocci G, et al. Angiogenesis and VEGF expression in pre-invasive lesions of the human breast. J Pathol. Oct. 2004;204(2):140-6. Not eligible outcomes. [pmid: 15376259].
2727 Viale G, Regan MM, Maiorano E, et al. Prognostic and predictive value of centrally reviewed expression of estrogen and progesterone receptors in a randomized trial comparing letrozole and tamoxifen adjuvant therapy for postmenopausal early breast cancer: BIG 1-98. J Clin Oncol. Sep. 1. 2007;25(25):3846-52. Not eligible target population. [pmid: 17679725].
2728 Vicini FA, Eberlein TJ, Connolly JL, et al. The optimal extent of resection for patients with stages I or II breast cancer treated with conservative surgery and radiotherapy. Ann Surg. Sep. 1991;214(3):200-4. discussion 4-5. Not eligible target population. [pmid: 1656901].
2729 Vicini FA, Goldstein NS, Pass H, et al. Use of pathologic factors to assist in establishing adequacy of excision before radiotherapy in patients treated with breast-conserving therapy. Int J Radiat Oncol Biol Phys. Sep. 1. 2004;60(1):86-94. Not eligible target population. [pmid: 15337543].
2730 Vicini FA, Kestin LL, Goldstein NS. Defining the clinical target volume for patients with early-stage breast cancer treated with lumpectomy and accelerated partial breast irradiation: a pathologic analysis. Int J Radiat Oncol Biol Phys. Nov. 1. 2004;60(3):722-30. Not eligible target population. [pmid: 15465188].
2731 Viehweg P, Bernerth T, Kiechle M, et al. MR-guided intervention in women with a family history of breast cancer. Eur J Radiol. Jan. 2006;57(1):81-9. Not eligible exposure. [pmid: 16364583].
2732 Viehweg P, Lampe D, Buchmann J, et al. In situ and minimally invasive breast cancer: morphologic and kinetic features on contrast-enhanced MR imaging. MAGMA. Dec. 2000;11(3):129-37. Not eligible level of evidence. [pmid: 11154954].
2733 Vieira CC, Mercado CL, Cangiarella JF, et al. Microinvasive ductal carcinoma in situ: Clinical presentation, imaging features, pathologic findings, and outcome. Eur J Radiol. 2008. Nov. 19. Not eligible level of evidence.
2734 Vielh P, Validire P, Kheirallah S, et al. Paget’s disease of the nipple without clinically and radiologically detectable breast tumor. Histochemical and immunohistochemical study of 44 cases. Pathol Res Pract. Mar. 1993;189(2):150-5. Not eligible target population. [pmid: 8391688].
2735 Vincens E, Alves K, Lauratet B, et al. Margin status in ductal carcinoma in situ of the breast. Bull Cancer. Dec. 2008;95(12):1155-9. Language. [pmid: 19091648].
2736 Vincent MD, Clink HM, Coombes RC, et al. Aminoglutethimide (with hydrocortisone) induced agranulocytosis in primary breast cancer. Br Med J (Clin Res Ed). Jul. 13. 1985;291(6488):105-6. Not eligible target population.
2737 Vinnicombe SJ, MacVicar AD, Guy RL, et al. Primary breast cancer: mammographic changes after neoadjuvant chemotherapy, with pathologic correlation. Radiology. Feb. 1996;198(2):333-40. Not eligible level of evidence. [pmid: 8596827].
2738 Visscher DW, Nanjia-Makker P, Heppner G, et al. Tamoxifen suppresses histologic progression to atypia and DCIS in MCFIOAT xenografts, a model of early human breast cancer. Breast Cancer Res Treat. Jan. 2001;65(1):41-7. Not eligible target population. [pmid: 11245338].
2739 Vogl G, Dietze O, Hauser-Kronberger C. Angiogenic potential of ductal carcinoma in situ (DCIS) of human breast. Histopathology. Dec. 2005;47(6):617-24. Not eligible outcomes. [pmid: 16324200].
2740 Voltura AM, Tsangaris TN, Rosson GD, et al. Nipple-sparing mastectomy: critical assessment of 51 procedures and implications for selection criteria. Ann Surg Oncol. Dec. 2008;15(12):3396-401. Not eligible outcomes. [pmid: 18923874].
2741 Vomweg TW, Teifke A, Kunz RP, et al. Combination of low and high resolution sequences in two orientations for dynamic contrast-enhanced MRI of the breast: more than a compromise. Eur Radiol. Oct. 2004;14(10):1732-42. Full text not available. [pmid: 15378253].
2742 von Rosen A, Frisell J, Nilsson R, et al. Histopathologic and cytochemical characteristics of interval breast carcinomas from the Stockholm Mammography Screening Project. Acta Oncol. 1992;31(4):399-402. Not eligible outcomes. [pmid: 1321649].
2743 von Rueden DG, Wilson RE. Intraductal carcinoma of the breast. Surg Gynecol Obstet. Feb. 1984;158(2):105-11. Comment. [pmid: 6320480].
2744 von Smitten K, Sundell B. The impact of adjuvant radiotherapy and cytotoxic chemotherapy on the outcome of immediate breast reconstruction by tissue expansion after mastectomy for breast cancer. Eur J Surg Oncol. Apr. 1992;18(2):119-23. Not eligible outcomes. [pmid: 1582504].
2745 Vona-Davis L, Rose DP, Hazard H, et al. Triple-negative breast cancer and obesity in a rural Appalachian population. Cancer Epidemiol Biomarkers Prev. Dec. 2008;17(12):3319-24. Not eligible target population. [pmid: 19064545].
2746 Vora SA, Wazer DE, Homer MJ. Management of microcalcifications that develop at the lumpectomy site after breast-conserving therapy. Radiology. Jun. 1997;203(3):667-71. Not eligible outcomes. [pmid: 9169686].
2747 Vorobiof DA, Kleeberg UR, Perez-Carrion R, et al. A randomized, open, parallel-group trial to compare the endocrine effects of oral anastrozole (Arimidex) with intramuscular formestane in postmenopausal women with advanced breast cancer. Ann Oncol. Oct. 1999;10(10):1219-25. Not eligible target population. [pmid: 10586340].
2748 Vos CB, ter Haar NT, Rosenberg C, et al. Genetic alterations on chromosome 16 and 17 are important features of ductal carcinoma in situ of the breast and are associated with histologic type. Br J Cancer. Dec. 1999;81(8):1410-8. Not eligible outcomes. [pmid: 10604741].
2749 Vowden P, Wilkinson D, Kester RC. Treatment of digital ischaemia associated with chemotherapy using the prostacyclin analogue iloprost. Eur J Vasc Surg. Oct. 1991;5(5):593-5. Case Reports. [pmid: 1720404].
2750 Vrouenraets BC, Peterse JL, van Dongen JA. Breast-conserving therapy of ductal carcinoma in situ: frequency of local recurrence after wide excision with and without additional radiotherapy, a retrospective study of 42 cases. Neth J Surg. Jun. 1991;43(3):51-5. Not eligible level of evidence. [pmid: 1656327].
2751 Waddell BE, Stomper PC, DeFazio JL, et al. Postexcision mammography is indicated after resection of ductal carcinoma-in-situ of the breast. Ann Surg Oncol. Oct. 2000;7(9):665-8. Not eligible outcomes. [pmid: 11034243].
2752 Wagner TD, Wharton K, Donohue K, et al. Pure tubular breast carcinoma: a 34 year study of outcomes. Breast J. Sep–Oct. 2008;14(5):512-3. Letter. [pmid: 18821938].
2753 Wagoner MJ, Laronga C, Acs G. Extent and histologic pattern of atypical ductal hyperplasia present on core needle biopsy specimens of the breast can predict ductal carcinoma in situ in subsequent excision. Am J Clin Pathol. Jan. 2009;131(1):112-21. Not eligible outcomes. [pmid: 19095574].
2754 Wahedna Y, Evans AJ, Pinder SE, et al. Mammographic size of ductal carcinoma in situ does not predict the presence of an invasive focus. Eur J Cancer. Mar. 2001;37(4):459-62. Not eligible outcomes. [pmid: 11267854].
2755 Wahner-Roedler DL, Reynolds C, Morton MJ. Spontaneous unilateral nipple discharge: when screening tests are negative--a case report and review of current diagnostic management of a pathologic nipple discharge. Breast J. Jan–Feb. 2003;9(1):49-52. Case Reports. [pmid: 12558673].
2756 Waldman FM, DeVries S, Chew KL, et al. Chromosomal alterations in ductal carcinomas in situ and their in situ recurrences. J Natl Cancer Inst. Feb. 16. 2000;92(4):313-20. Not eligible outcomes. [pmid: 10675380].
2757 Waljee JF, Hawley S, Alderman AK, et al. Patient satisfaction with treatment of breast cancer: does surgeon specialization matter. J Clin Oncol. Aug. 20. 2007;25(24):3694-8. Not eligible outcomes. [pmid: 17635952].
2758 Walker AN, Fechner RE. Papillary carcinoma arising from ectopic breast tissue in an axillary lymph node. Diagn Gynecol Obstet. Summer. 1982;4(2):141-5. Case Reports. [pmid: 6284467].
2759 Walker RA, Dearing SJ, Brown LA. Comparison of pathological and biological features of symptomatic and mammographically detected ductal carcinoma in situ of the breast. Hum Pathol. Aug. 1999;30(8):943-8. Not eligible outcomes. [pmid: 10452507].
2760 Wallace AM, Daniel BL, Jeffrey SS, et al. Rates of reexcision for breast cancer after magnetic resonance imaging-guided bracket wire localization. J Am Coll Surg. Apr. 2005;200(4):527-37. Not eligible exposure. [pmid: 15804466].
2761 Wallace AM, Evans GR, Goldberg DP, et al. Unexpected vascular compromise in transverse rectus abdominis musculocutaneous (TRAM) flap reconstruction: a report of two patients. Ann Plast Surg. Mar. 1996;36(3):246-50. Case Reports. [pmid: 8659946].
2762 Wallwiener D, Schmit H, Rimbach S, et al. Laser palliation of locoregional recurrences of breast cancer. Eur J Gynaecol Oncol. 1991;12(5):351-7. Case Reports. [pmid: 1717277].
2763 Wang H, Jebsen PW, Karesen R, et al. Ductal carcinoma in situ of the breast--a review of diagnosis, treatment and outcome in a hospital-based Norwegian series. Acta Oncol. 2000;39(2):131-4. Not eligible level of evidence. [pmid: 10859000].
2764 Wang HH, Ducatman BS, Eick D. Comparative features of ductal carcinoma in situ and infiltrating ductal carcinoma of the breast on fine-needle aspiration biopsy. Am J Clin Pathol. Dec. 1989;92(6):736-40. Not eligible outcomes. [pmid: 2556017].
2765 Wang J, Costantino JP, Tan-Chiu E, et al. Lower-category benign breast disease and the risk of invasive breast cancer. J Natl Cancer Inst. Apr. 21. 2004;96(8):616-20. Not eligible outcomes. [pmid: 15100339].
2766 Wang L, Hoque A, Luo RZ, et al. Loss of the expression of the tumor suppressor gene ARHI is associated with progression of breast cancer. Clin Cancer Res. Sep. 1. 2003;9(10 Pt 1):3660-6. Not eligible outcomes. [pmid: 14506155].
2767 Wang R, Luo D, Ma X, et al. Antisense Ki-67 cDNA transfection reverses the tumorigenicity and induces apoptosis in human breast cancer cells. Cancer Invest. Oct. 2008;26(8):830-5. Not eligible outcomes. [pmid: 18798062].
2768 Wang X, Mori I, Tang W, et al. p63 expression in normal, hyperplastic and malignant breast tissues. Breast Cancer. 2002;9(3):216-9. Not eligible outcomes. [pmid: 12185332].
2769 Wang-Johanning F, Frost AR, Jian B, et al. Quantitation of HERV-K env gene expression and splicing in human breast cancer. Oncogene. Mar. 13. 2003;22(10):1528-35. Not eligible outcomes. [pmid: 12629516].
2770 Wapnir IL, Alden-Corbett S, Zicherman B, et al. Mammographic changes following biopsy and lumpectomy-breast irradiation. N J Med. Jan. 1993;90(1):55-9. Not eligible outcomes. [pmid: 8380491].
2771 Ward BA, Latrenta L. Re-excision for ductal carcinoma in situ: the surgeon’s least favorite operation. Cancer J. Jan–Feb. 2006;12(1):14-6. Comment. [pmid: 16613655].
2772 Ward BA, McKhann CF, Ravikumar TS. Ten-year follow-up of breast carcinoma in situ in Connecticut. Arch Surg. Dec. 1992;127(12):1392-5. Not eligible target population. [pmid: 1365682].
2773 Wargotz ES, Norris HJ. Metaplastic carcinomas of the breast. IV. Squamous cell carcinoma of ductal origin. Cancer. Jan. 15. 1990;65(2):272-6. Not eligible target population. [pmid: 2153044].
2774 Warnberg F, Bergh J, Holmberg L. Prognosis in women with a carcinoma in situ of the breast: a population-based study in Sweden. Cancer Epidemiol Biomarkers Prev. Sep. 1999;8(9):769-74. Not eligible target population. [pmid: 10498395].
2775 Warnberg F, White D, Anderson E, et al. Effect of a farnesyl transferase inhibitor (R115777) on ductal carcinoma in situ of the breast in a human xenograft model and on breast and ovarian cancer cell growth in vitro and in vivo. Breast Cancer Res. 2006;8(2):R21. Not eligible target population. [pmid: 16611371].
2776 Warner E, Causer PA. MRI surveillance for hereditary breast-cancer risk. Lancet. May. 21–27. 2005;365(9473):1747-9. Comment. [pmid: 15910935].
2777 Warren RM, Young JR, McLean L, et al. Radiology review of the UKCCCR Breast Screening Frequency Trial: potential improvements in sensitivity and lead time of radiological signs. Clin Radiol. Feb. 2003;58(2):128-32. Not eligible outcomes. [pmid: 12623041].
2778 Wasan KM, Goss PE, Pritchard PH, et al. The influence of letrozole on serum lipid concentrations in postmenopausal women with primary breast cancer who have completed 5 years of adjuvant tamoxifen (NCIC CTG MA.17L). Ann Oncol. May. 2005;16(5):707-15. Not eligible target population. [pmid: 15817595].
2779 Wasserberg N, Morgenstern S, Schachter J, et al. Risk factors for lymph node metastases in breast ductal carcinoma in situ with minimal invasive component. Arch Surg. Nov. 2002;137(11):1249-52. Not eligible level of evidence. [pmid: 12413311].
2780 Wasserman LJ, Apffelstaedt JP, Odendaal Jde V. Conservative management of breast cancer in the elderly in a developing country. World J Surg Oncol. 2007;5:108. Not eligible target population. [pmid: 17908323].
2781 Watanabe D, Inoue H, Akiyoshi T. Extraskeletal osteosarcoma in the axilla associated with breast carcinoma. Eur J Surg Oncol. Jun. 1991;17(3):319-22. Case Reports. [pmid: 1646130].
2782 Watermann DO, Tempfer CB, Hefler LA, et al. Ultrasound criteria for ductal invasive breast cancer are modified by age, tumor size, and axillary lymph node status. Breast Cancer Res Treat. Jan. 2005;89(2):127-33. Not eligible target population. [pmid: 15692754].
2783 Watier E, Leveque J, Pioud R, et al. Immediate breast reconstruction with deepidermalized transverse rectus abdominis musculocutaneous flap after skin-sparing mastectomy. Eur J Obstet Gynecol Reprod Biol. May. 1999;84(1):17-21. Case Reports. [pmid: 10413221].
2784 Watkins JM, Harper JL, Dragun AE, et al. Incidence and prognostic factors for seroma development after MammoSite breast brachytherapy. Brachytherapy. Oct–Dec. 2008;7(4):305-9. Not eligible outcomes. [pmid: 18778970].
2785 Watson DP, McGuire M, Nicholson F, et al. Aspiration cytology and its relevance to the diagnosis of solid tumors of the breast. Surg Gynecol Obstet. Nov. 1987;165(5):435-41. Not eligible outcomes. [pmid: 2823401].
2786 Waxler B, Wezeman FH. Low molecular weight proteinase inhibitors. I. Extraction and identification of activity from normal and malignant human breast tissues. Br J Exp Pathol. Jun. 1983;64(3):252-60. Not eligible outcomes. [pmid: 6309206].
2787 Waxler B, Wezeman FH. Low molecular weight proteinase inhibitors. II. Extraction and identification of activity from infiltrating ductal carcinoma during lactation. Br J Exp Pathol. Dec. 1983;64(6):626-32. Not eligible outcomes. [pmid: 6318792].
2788 Wazer DE, Gage I, Homer MJ, et al. Age-related differences in patients with nonpalpable breast carcinomas. Cancer. Oct. 1. 1996;78(7):1432-7. Not eligible target population. [pmid: 8839548].
2789 Wazer DE, Morr J, Erban JK, et al. The effects of postradiation treatment with tamoxifen on local control and cosmetic outcome in the conservatively treated breast. Cancer. Aug. 15. 1997;80(4):732-40. Not eligible target population. [pmid: 9264357].
2790 Weaver MG, Abdul-Karim FW, al-Kaisi N. Mucinous lesions of the breast. A pathological continuum. Pathol Res Pract. Sep. 1993;189(8):873-6. Not eligible outcomes. [pmid: 8302709].
2791 Weber WP, Engelberger S, Viehl CT, et al. Accuracy of frozen section analysis versus specimen radiography during breast-conserving surgery for nonpalpable lesions. World J Surg. Dec. 2008;32(12):2599-606. Not eligible outcomes. [pmid: 18836763].
2792 Webster LR, Bilous AM, Willis L, et al. Histopathologic indicators of breast cancer biology: insights from population mammographic screening. Br J Cancer. Apr. 25. 2005;92(8):1366-71. Not eligible outcomes. [pmid: 15812557].
2793 Webster LR, Lee SF, Ringland C, et al. Poor-prognosis estrogen receptor-positive breast cancer identified by histopathologic subclassification. Clin Cancer Res. Oct. 15. 2008;14(20):6625-33. Not eligible target population. [pmid: 18927304].
2794 Wei B, Wang J, Bourne P, et al. Bone metastasis is strongly associated with estrogen receptor-positive/progesterone receptor-negative breast carcinomas. Hum Pathol. Dec. 2008;39(12):1809-15. Not eligible target population. [pmid: 18715613].
2795 Weigelt B, Horlings HM, Kreike B, et al. Refinement of breast cancer classification by molecular characterization of histological special types. J Pathol. Oct. 2008;216(2):141-50. Not eligible target population. [pmid: 18720457].
2796 Weight SC, Windle R, Stotter AT. Optimizing surveillance mammography following breast conservation surgery. Eur J Surg Oncol. Feb. 2002;28(1):11-3. Not eligible target population. [pmid: 11869006].
2797 Weiss H, Brasching HP, Bock A, et al. Mitotic rate, DNA distribution, and chromatin in situ sensitivity to heparin in breast cancer. Breast Cancer Res Treat. Jul. 1990;16(1):41-50. Not eligible exposure. [pmid: 2169927].
2798 Weiss H, Kunde D, Streller B. DNA distributions in human normal, precancerous and cancerous breast tissue. I. Ploidy and cell cycle distribution. Arch Geschwulstforsch. 1986;56(5):373-9. Not eligible outcomes. [pmid: 3021084].
2799 Weiss MC, Fowble BL, Solin LJ, et al. Outcome of conservative therapy for invasive breast cancer by histologic subtype. Int J Radiat Oncol Biol Phys. 1992;23(5):941-7. Not eligible target population. [pmid: 1322387].
2800 Wellings SR, Jensen HM, Marcum RG. An atlas of subgross pathology of the human breast with special reference to possible precancerous lesions. J Natl Cancer Inst. Aug. 1975;55(2):231-73. Not eligible outcomes. [pmid: 169369].
2801 Wells CA, McGregor IL, Makunura CN, et al. Apocrine adenosis: a precursor of aggressive breast cancer. J Clin Pathol. Aug. 1995;48(8):737-42. Not eligible outcomes. [pmid: 7560201].
2802 Weng EY, Juillard GJ, Parker RG, et al. Outcomes and factors impacting local recurrence of ductal carcinoma in situ. Cancer. Apr. 1. 2000;88(7):1643-9. Not eligible level of evidence. [pmid: 10738223].
2803 Wenkel E, Heckmann M, Heinrich M, et al. Automated breast ultrasound: lesion detection and BI-RADS classification--a pilot study. Rofo. Sep. 2008;180(9):804-8. Not eligible exposure. [pmid: 18704878].
2804 Werling RW, Hwang H, Yaziji H, et al. Immunohistochemical distinction of invasive from noninvasive breast lesions: a comparative study of p63 versus calponin and smooth muscle myosin heavy chain. Am J Surg Pathol. Jan. 2003;27(1):82-90. Not eligible outcomes. [pmid: 12502930].
2805 Werner M, Mattis A, Aubele M, et al. 20q13.2 amplification in intraductal hyperplasia adjacent to in situ and invasive ductal carcinoma of the breast. Virchows Arch. Nov. 1999;435(5):469-72. Not eligible outcomes. [pmid: 10592049].
2806 Westenend PJ, Liem SJ. Adenosis tumor of the breast containing ductal carcinoma in situ, a pitfall in core needle biopsy. Breast J. May–Jun. 2001;7(3):200-1. Case Reports. [pmid: 11469938].
2807 Wheeler JE, Enterline HT, Roseman JM, et al. Lobular carcinoma in situ of the breast. Long-term followup. Cancer. Sep. 1974;34(3):554-63. Not eligible target population. [pmid: 4853024].
2808 Whelan TJ, Goss PE, Ingle JN, et al. Assessment of quality of life in MA.17: a randomized, placebo-controlled trial of letrozole after 5 years of tamoxifen in postmenopausal women. J Clin Oncol. Oct. 1. 2005;23(28):6931-40. Not eligible target population. [pmid: 16157934].
2809 White J, Levine A, Gustafson G, et al. Outcome and prognostic factors for local recurrence in mammographically detected ductal carcinoma in situ of the breast treated with conservative surgery and radiation therapy. Int J Radiat Oncol Biol Phys. Feb. 15. 1995;31(4):791-7. Not eligible level of evidence. [pmid: 7860390].
2810 White J, Morrow M, Moughan J, et al. Compliance with breast-conservation standards for patients with early-stage breast carcinoma. Cancer. Feb. 15. 2003;97(4):893-904. Not eligible outcomes. [pmid: 12569588].
2811 White V, Pruden M, Giles G, et al. Changes in the management of ductal carcinoma in situ before the release of clinical practice recommendations in Australia: the case in Victoria. ANZ J Surg. Jan–Feb. 2006;76(1-2):28-34. Not eligible outcomes. [pmid: 16483292].
2812 Whitlock JP, Evans AJ, Burrell HC, et al. Digital imaging improves upright stereotactic core biopsy of mammographic microcalcifications. Clin Radiol. May. 2000;55(5):374-7. Not eligible outcomes. [pmid: 10816404].
2813 Wiech T, Nikolopoulos E, Hausmann M, et al. A case of heterogeneous breast cancer with clonally expanded T-Cells in the HER2+ and metastasis of the HER2- tumor cells. Breast J. Sep–Oct. 2008;14(5):487-91. Not eligible outcomes. [pmid: 18821935].
2814 Wieland AW, Louwman MW, Voogd AC, et al. Determinants of prognosis in breast cancer patients with tumor involvement of the skin (pT4b). Breast J. Mar–Apr. 2004;10(2):123-8. Not eligible target population. [pmid: 15009039].
2815 Wijayanayagam A, Kumar AS, Foster RD, et al. Optimizing the total skin-sparing mastectomy. Arch Surg. Jan. 2008;143(1):38-45. discussion. Not eligible level of evidence. [pmid: 18209151].
2816 Wilcken NR. Tamoxifen hits the target in situ. Lancet. Jun. 12. 1999;353(9169):1986-7. Comment. [pmid: 10376607].
2817 Wiley EL, Diaz LK, Badve S, et al. Effect of time interval on residual disease in breast cancer. Am J Surg Pathol. Feb. 2003;27(2):194-8. Not eligible target population. [pmid: 12548165].
2818 Willett CG, Lewandrowski K, Warshaw AL, et al. Resection margins in carcinoma of the head of the pancreas. Implications for radiation therapy. Ann Surg. Feb. 1993;217(2):144-8. Not eligible target population. [pmid: 8094952].
2819 Williams CJ, Barley VL, Blackledge GR, et al. Multicentre cross over study of aminoglutethimide and trilostane in advanced postmenopausal breast cancer. Br J Cancer. Dec. 1993;68(6):1210-5. Not eligible target population. [pmid: 8260375].
2820 Williams CJ, Barley VL, Blackledge GR, et al. Multicentre cross-over study of aminoglutethimide and trilostane in advanced postmenopausal breast cancer. Clin Oncol (R Coll Radiol). 1995;7(2):87-92. Not eligible target population. [pmid: 7619769].
2821 Williams MB, More MJ, Narayanan D, et al. Combined structural and functional imaging of the breast. Technol Cancer Res Treat. Feb. 2002;1(1):39-42. Not eligible outcomes. [pmid: 12614175].
2822 Willsher PC, Leach IH, Ellis IO, et al. A comparison outcome of male breast cancer with female breast cancer. Am J Surg. Mar. 1997;173(3):185-8. Not eligible target population. [pmid: 9124623].
2823 Wilson AR. Contrast-enhanced breast ultrasound. The clinical context. Eur Radiol. 2001;11(Suppl 3):E35-40. Not eligible outcomes. [pmid: 11793051].
2824 Wilson JF, Destouet JM, Winchester DP, et al. 1991 RSNA special focus session: current controversies in the management of ductal carcinoma in situ of the breast. Radiology. Oct. 1992;185(1):77-81. Comment. [pmid: 1326120].
2825 Wilson LD, Beinfield M, McKhann CF, et al. Conservative surgery and radiation in the treatment of synchronous ipsilateral breast cancers. Cancer. Jul. 1. 1993;72(1):137-42. Not eligible target population. [pmid: 8389664].
2826 Winchester DJ, Bernstein JR, Jeske JM, et al. Upstaging of atypical ductal hyperplasia after vacuum-assisted 11-gauge stereotactic core needle biopsy. Arch Surg. Jun. 2003;138(6):619-22. discussion 22-3. Not eligible outcomes. [pmid: 12799332].
2827 Winchester DJ, Duda RB, August CZ, et al. The importance of DNA flow cytometry in node-negative breast cancer. Arch Surg. Jul. 1990;125(7):886-9. Not eligible target population. [pmid: 2164372].
2828 Winchester DJ, Menck HR, Winchester DP. National treatment trends for ductal carcinoma in situ of the breast. Arch Surg. Jun. 1997;132(6):660-5. Not eligible outcomes. [pmid: 9197860].
2829 Winchester DP, Menck HR, Osteen RT, et al. Treatment trends for ductal carcinoma in situ of the breast. Ann Surg Oncol. May. 1995;2(3):207-13. Not eligible outcomes. [pmid: 7641016].
2830 Winchester DP, Murphy GP, Bowman HE, et al. Surgical management of stages 0, I, and IIA breast cancer. Cancer. May. 1. 1990;65(9 Suppl):2105-7. Not eligible target population. [pmid: 2158391].
2831 Winchester DP, Osteen RT, Menck HR. The National Cancer Data Base report on breast carcinoma characteristics and outcome in relation to age. Cancer. Oct. 15. 1996;78(8):1838-43. Not eligible target population. [pmid: 8859200].
2832 Winslet MC, Obeid ML. Submammary approach for the excision of mammographically localised lesions of the breast. Eur J Surg. Apr. 1994;160(4):209-11. Case Reports. [pmid: 8049310].
2833 Winston JS, Asch HL, Zhang PJ, et al. Downregulation of gelsolin correlates with the progression to breast carcinoma. Breast Cancer Res Treat. Jan. 2001;65(1):11-21. Not eligible outcomes. [pmid: 11245335].
2834 Winston JS, Geradts J, Liu DF, et al. Microtome shaving radiography: demonstration of loss of mammographic microcalcifications during histologic sectioning. Breast J. May–Jun. 2004;10(3):200-3. Case Reports. [pmid: 15125745].
2835 Wiratkapun C, Wibulpholprasert B, Lertsithichai P, et al. Breast cancer underestimation rate of atypical ductal hyperplasia diagnosed by core-needle biopsy under imaging guidance. J Med Assoc Thai. Apr. 2005;88(4):460-6. Not eligible outcomes. [pmid: 16146248].
2836 Wiratkapun C, Wibulpolprasert B, Lertsithichai P. Breast cancer in patients initially assigned as BI-RADS category 3. J Med Assoc Thai. Jun. 2006;89(6):834-9. Not eligible outcomes. [pmid: 16850685].
2837 Witkiewicz AK, Varambally S, Shen R, et al. Alpha-methylacyl-CoA racemase protein expression is associated with the degree of differentiation in breast cancer using quantitative image analysis. Cancer Epidemiol Biomarkers Prev. Jun. 2005;14(6):1418-23. Not eligible outcomes. [pmid: 15941950].
2838 Witmer DR, Dickson-Witmer D, Teixido R. Initial 100 consecutive stereotactic core breast biopsies in a private breast center setting. Del Med J. Jun. 1997;69(6):297-301. Not eligible outcomes. [pmid: 9203750].
2839 Witt A, Obwegeser R, Auerbach L, et al. Axillary lymph node dissection in pT1 breast cancer: a retrospective analysis of 315 patients and review of the literature. Wien Klin Wochenschr. Jun. 14. 10. 2002:114-11. 387. 90. Not eligible target population.
2840 Wobbes T, Tinnemans JG, van der Sluis RF. Residual tumour after biopsy for non-palpable ductal carcinoma in situ of the breast. Br J Surg. Feb. 1989;76(2):185-6. Not eligible outcomes. [pmid: 2539223].
2841 Wolf I, Bose S, Desmond JC, et al. Unmasking of epigenetically silenced genes reveals DNA promoter methylation and reduced expression of PTCH in breast cancer. Breast Cancer Res Treat. Oct. 2007;105(2):139-55. Not eligible outcomes. [pmid: 17295047].
2842 Wolf R, Bernstein-Lipschitz L, Rothem A. Paget’s disease of the nipple resembling an acantholytic disease on microscopic examination. Dermatologica. 1989;179(1):42-4. Not eligible target population. [pmid: 2548901].
2843 Wolfe JN. Mammography. Radiol Clin North Am. Apr. 1974;12(1):189-203. Comment. [pmid: 4362425].
2844 Wolfe JN. Developments in mammography. Am J Obstet Gynecol. Feb. 1. 1976;124(3):312-23. Review. [pmid: 174430].
2845 Wolfram D, Schoeller T, Hussl H, et al. The superficial inferior epigastric artery (SIEA) flap: indications for breast reconstruction. Ann Plast Surg. Dec. 2006;57(6):593-6. Not eligible exposure. [pmid: 17122541].
2846 Wolman SR, Feiner HD, Schinella RA, et al. A retrospective analysis of breast cancer based on outcome differences. Hum Pathol. May. 1991;22(5):475-80. Not eligible target population. [pmid: 1674493].
2847 Wolverton DE, Sickles EA. Clinical outcome of doubtful mammographic findings. AJR Am J Roentgenol. Oct. 1996;167(4):1041-5. Not eligible target population. [pmid: 8819409].
2848 Wong A, Chan A. Survival benefit of tamoxifen therapy in adenocarcinoma of pancreas. A case-control study. Cancer. Apr. 1. 1993;71(7):2200-3. Not eligible target population. [pmid: 8384066].
2849 Wong JH, Kopald KH, Morton DL. The impact of microinvasion on axillary node metastases and survival in patients with intraductal breast cancer. Arch Surg. Oct. 1990;125(10):1298-301. discussion 301-2. Not eligible level of evidence. [pmid: 2171453].
2850 Wong ST, Chen W, Bottorff JL, et al. Treatment decision making among Chinese women with DCIS. J Psychosoc Oncol. 2008;26(4):53-73. Not eligible outcomes. [pmid: 19042272].
2851 Wong TC, Lim J, Lim TC. A case of ductal carcinoma in situ of breast with Poland syndrome. Ann Acad Med Singapore. May. 2004;33(3):382-4. Case Reports. [pmid: 15175787].
2852 Woo SU, Bae JW, Yang JH, et al. Overexpression of interleukin-10 in sentinel lymph node with breast cancer. Ann Surg Oncol. Nov. 2007;14(11):3268-73. Not eligible target population. [pmid: 17762971].
2853 Wood WC. The role of clinical trials in changing therapy for ductal carcinoma in situ. Ann Surg Oncol. Jan. 2004;11(1 Suppl):24S-7S. No primary data. [pmid: 15015706].
2854 Worsham MJ, Pals G, Schouten JP, et al. High-resolution mapping of molecular events associated with immortalization, transformation, and progression to breast cancer in the MCF10 model. Breast Cancer Res Treat. Mar. 2006;96(2):177-86. Not eligible outcomes. [pmid: 16319984].
2855 Wright H, Listinsky J, Quinn C, et al. Increased ipsilateral whole breast vascularity as measured by contrast-enhanced magnetic resonance imaging in patients with breast cancer. Am J Surg. Oct. 2005;190(4):576-9. Not eligible outcomes. [pmid: 16164924].
2856 Wu W, Kamma H, Ueno E, et al. The intraductal component of breast cancer is poorly responsive to neo-adjuvant chemotherapy. Oncol Rep. Sep–Oct. 2002;9(5):1027-31. Not eligible outcomes. [pmid: 12168068].
2857 Wu X, Chen VW, Ruiz B, et al. Patterns of treatment for ductal carcinoma in situ of the breast in Louisiana, 1988-1999. J La State Med Soc. Jul–Aug. 2003;155(4):206-13. Full text was not available. [pmid: 14506828].
2858 Wu YC, Chen DR, Kuo SJ. Personal experience of ultrasound-guided 14-gauge core biopsy of breast tumor. Eur J Surg Oncol. Sep. 2006;32(7):715-8. Not eligible outcomes. [pmid: 16769196].
2859 Wulf GM, Ryo A, Wulf GG, et al. Pin1 is overexpressed in breast cancer and cooperates with Ras signaling in increasing the transcriptional activity of c-Jun towards cyclin D1. EMBO J. Jul. 2. 2001;20(13):3459-72. Not eligible outcomes. [pmid: 11432833].
2860 Wulfing P, Diallo R, Kersting C, et al. Endothelin-1, Endothelin-A- and Endothelin-B-receptor expression in preinvasive and invasive breast disease. Oncol Rep. Apr. 2004;11(4):791-6. Not eligible outcomes. [pmid: 15010874].
2861 Wunderbaldinger P, Helbich TH, Partik B, et al. First experience with a new dedicated ultrasound system for computer-guided large-core breast biopsy. Eur Radiol. 2001;11(12):2460-4. Not eligible outcomes. [pmid: 11734940].
2862 Xu J, Souter LH, Chambers AF, et al. Distinct karyotypes in three breast cancer cell lines --21PTCi, 21NTCi, and 21MT-1 --derived from the same patient and representing different stages of tumor progression. Cancer Genet Cytogenet. Oct. 2008;186(1):33-40. Not eligible outcomes. [pmid: 18786440].
2863 Xu WG, Wang G, Liu Y, et al. Expression of vascular endothelial growth factor in different breast tissues and clinical significance thereof. Zhonghua Yi Xue Za Zhi. Mar. 25. 2008;88(12):802-4. Language. [pmid: 18756980].
2864 Yagmurdur MC, Atac FB, Tutar NU, et al. Prognostic value of the PAI-1 4G/5G polymorphism in invasive ductal carcinoma of the breast. Int Surg. May–Jun. 2008;93(3):163-8. Not eligible target population. [pmid: 18828272].
2865 Yamada T, Saito M, Ishibashi T, et al. Comparison of screen-film and full-field digital mammography in Japanese population-based screening. Radiat Med. 2004;11; 22(6):408-12. Not eligible outcomes.
2866 Yamaguchi J, Ohtani H, Nakamura K, et al. Prognostic impact of marginal adipose tissue invasion in ductal carcinoma of the breast. Am J Clin Pathol. Sep. 2008;130(3):382-8. Not eligible target population. [pmid: 18701411].
2867 Yamaguchi K, Shimizu S, Yokohata K, et al. Ductal branch-oriented minimal pancreatectomy: two cases of successful treatment. J Hepatobiliary Pancreat Surg. 1999;6(1):69-73. Case Reports. [pmid: 10436239].
2868 Yamaguchi R, Tanaka M, Kishimoto Y, et al. Ductal carcinoma in situ arising in a benign phyllodes tumor: report of a case. Surg Today. 2008;38(1):42-5. Case Reports. [pmid: 18085361].
2869 Yamamoto K, Kawakami H, Sugiyama M, et al. Immunohistochemical localization of beta-1,4-galactosyltransferase in human pancreatic tissues. Pancreas. Aug. 1999;19(2):137-42. Not eligible target population. [pmid: 10438160].
2870 Yang M, Moriya T, Oguma M, et al. Microinvasive ductal carcinoma (T1mic) of the breast. The clinicopathological profile and immunohistochemical features of 28 cases. Pathol Int. Jul. 2003;53(7):422-8. Not eligible outcomes. [pmid: 12828606].
2871 Yang SK, Cho N, Moon WK. The role of PET/CT for evaluating breast cancer. Korean J Radiol. Sep–Oct. 2007;8(5):429-37. Not eligible outcomes. [pmid: 17923786].
2872 Yang SK, Moon WK, Cho N, et al. Screening mammography-detected cancers: sensitivity of a computer-aided detection system applied to full-field digital mammograms. Radiology. Jul. 2007;244(1):104-11. Not eligible outcomes. [pmid: 17507722].
2873 Yang WT, Dryden M, Broglio K, et al. Mammographic features of triple receptor-negative primary breast cancers in young premenopausal women. Breast Cancer Research & Treatment. Oct. 2008;111(3):405-10. Not eligible outcomes. [pmid: 18026834].
2874 Yang WT, Tse GM. Sonographic, mammographic, and histopathologic correlation of symptomatic ductal carcinoma in situ. AJR Am J Roentgenol. Jan. 2004;182(1):101-10. Not eligible outcomes. [pmid: 14684521].
2875 Yang WT, Yu L, Lu HF, et al. Clinicopathologic study of intracystic papillary carcinoma of the breast. Zhonghua Bing Li Xue Za Zhi. Apr. 2008;37(4):234-7. Language. [pmid: 18844031].
2876 Yankaskas BC, Schell MJ, Bird RE, et al. Reassessment of breast cancers missed during routine screening mammography: a community-based study. AJR Am J Roentgenol. Sep. 2001;177(3):535-41. Not eligible target population. [pmid: 11517043].
2877 Yasumura T, Matsui S, Hamajima T, et al. Infiltrating ductal carcinoma developing within cystosarcoma phyllodes--a case report. Jpn J Surg. May. 1988;18(3):326-9. Case Reports. [pmid: 2841520].
2878 Yau TK, Chan K, Chant M, et al. Wide local excision and radiotherapy for the treatment of ductal carcinoma in situ of the breast: the Hong Kong experience. Clin Oncol (R Coll Radiol). Aug. 2006;18(6):447-52. Not eligible level of evidence. [pmid: 16909967].
2879 Yau TK, Lau Y, Kong J, et al. Breast conservation treatment in Hong Kong-early results of 203 patients: retrospective study. Hong Kong Med J. Oct. 2002;8(5):322-8. Not eligible level of evidence. [pmid: 12376708].
2880 Yavuz S, Paydas S, Disel U, et al. VEGF-C expression in breast cancer: clinical importance. Adv Ther. Jul–Aug. 2005;22(4):368-80. Not eligible target population. [pmid: 16418144].
2881 Yeh CN, Jan YY, Yeh TS, et al. Hepatic resection of the intraductal papillary type of peripheral cholangiocarcinoma. Ann Surg Oncol. Jun. 2004;11(6):606-11. Not eligible target population. [pmid: 15172934].
2882 Yeh ED. Characterization of breast lesions with proton MR spectroscopy. AJR Am J Roentgenol. Nov. 2003;181(5):1273-4. Comment. [pmid: 14573419].
2883 Yen MF, Tabar L, Vitak B, et al. Quantifying the potential problem of overdiagnosis of ductal carcinoma in situ in breast cancer screening. Eur J Cancer. Aug. 2003;39(12):1746-54. Not eligible outcomes. [pmid: 12888370].
2884 Yen TW, Hunt KK, Mirza NQ, et al. Physician recommendations regarding tamoxifen and patient utilization of tamoxifen after surgery for ductal carcinoma in situ. Cancer. Mar. 1. 2004;100(5):942-9. Not eligible outcomes. [pmid: 14983489].
2885 Yen TW, Kuerer HM, Ottesen RA, et al. Impact of randomized clinical trial results in the national comprehensive cancer network on the use of tamoxifen after breast surgery for ductal carcinoma in situ. J Clin Oncol. Aug. 1. 2007;25(22):3251-8. Not eligible outcomes. [pmid: 17577019].
2886 Yen TW, Mann GN, Lawton TJ, et al. An axillary recurrence of breast cancer following a negative sentinel lymph node biopsy. Breast J. May–Jun. 2003;9(3):234-6. Case Reports. [pmid: 12752634].
2887 Yerushalmi R, Sulkes A, Mishaeli M, et al. Radiation treatment for ductal carcinoma in situ (DCIS): is a boost to the tumor bed necessary. Neoplasma. 2006;53(6):507-10. Not eligible level of evidence. [pmid: 17167720].
2888 Yeung DK, Yang WT, Tse GM. Breast cancer: in vivo proton MR spectroscopy in the characterization of histopathologic subtypes and preliminary observations in axillary node metastases. Radiology. Oct. 2002;225(1):190-7. Not eligible outcomes. [pmid: 12355004].
2889 Yiangou C, Shousha S, Sinnett HD. Primary tumour characteristics and axillary lymph node status in breast cancer. Br J Cancer. Aug. 1999;80(12):1974-8. Not eligible outcomes. [pmid: 10471048].
2890 Yildiz A, Colak T, Gungor F, et al. Diagnostic value of 99mTc MIBI scintimammography in patients with breast lesions. Rev Esp Med Nucl. Jun. 2001;20(4):276-81. Not eligible outcomes. [pmid: 11440709].
2891 Yim JH, Wick MR, Philpott GW, et al. Underlying pathology in mammary Paget’s disease. Ann Surg Oncol. Jun. 1997;4(4):287-92. Not eligible target population. [pmid: 9181226].
2892 Yin H, Schinella R. Cytologic characteristics of endocrine ductal carcinoma in situ of the breast. A case report. Acta Cytol. Sep–Oct. 2002;46(5):873-6. Case Reports. [pmid: 12365222].
2893 Yin XL, Pang JC, Ng HK. Identification of a region of homozygous deletion on 8p22-23.1 in medulloblastoma. Oncogene. Feb. 21. 2002;21(9):1461-8. Not eligible target population. [pmid: 11857089].
2894 Yoshikawa MI, Ohsumi S, Sugata S, et al. Comparison of breast cancer detection by diffusion-weighted magnetic resonance imaging and mammography. Radiat Med. Jun. 2007;25(5):218-23. Not eligible outcomes. [pmid: 17581710].
2895 Yoshimoto M, Kasumi F, Iwase T, et al. Magnetic resonance galactography for a patient with nipple discharge. Breast Cancer Res Treat. Jan. 1997;42(1):87-90. Case Reports. [pmid: 9116323].
2896 Yoshimura T, Manabe T, Imamura T, et al. Flow cytometric analysis of nuclear DNA content of duct cell carcinoma of the pancreas. Cancer. Sep. 1. 1992;70(5):1069-74. Not eligible target population. [pmid: 1325268].
2897 Youk JH, Kim EK, Kim MJ, et al. Sonographically guided 14-gauge core needle biopsy of breast masses: a review of 2,420 cases with long-term follow-up. AJR Am J Roentgenol. Jan. 2008;190(1):202-7. Not eligible outcomes. [pmid: 18094312].
2898 Young KB, Satovsky N. The vertical pattern breast reconstruction for large or ptotic breasts. Plast Reconstr Surg. Jun. 2005;115(7):2052-5. Case Reports. [pmid: 15923854].
2899 Youngson BJ, Cranor M, Rosen PP. Epithelial displacement in surgical breast specimens following needling procedures. Am J Surg Pathol. Sep. 1994;18(9):896-903. Not eligible outcomes. [pmid: 8067510].
2900 Yu H, Gong X, Luo X, et al. Co-expression of EGFRvIII with ErbB-2 enhances tumorigenesis: EGFRvIII mediated constitutively activated and sustained signaling pathways, whereas EGF-induced a transient effect on EGFR-mediated signaling pathways. Cancer Biol Ther. Nov. 24. 2008;7(11). Not eligible outcomes.
2901 Yu M, Tang Z, Alousi S, et al. Expression patterns of lymphangiogenic and angiogenic factors in a model of breast ductal carcinoma in situ. Am J Surg. Nov. 2007;194(5):594-9. Not eligible outcomes. [pmid: 17936419].
2902 Yuan Y, Liu H, Sahin A, et al. Reactivation of SYK expression by inhibition of DNA methylation suppresses breast cancer cell invasiveness. Int J Cancer. Feb. 10. 2005;113(4):654-9. Not eligible outcomes. [pmid: 15455373].
2903 Yuen S, Uematsu T, Masako K, et al. Segmental enhancement on breast MR images: differential diagnosis and diagnostic strategy. European radiology. Oct. 2008;18(10):2067-75. Not eligible outcomes. [pmid: 18491098].
2904 Yunes MJ, Neuschatz AC, Bornstein LE, et al. Loss of expression of the putative tumor suppressor NES1 gene in biopsy-proven ductal carcinoma in situ predicts for invasive carcinoma at definitive surgery. Int J Radiat Oncol Biol Phys. Jul. 1. 2003;56(3):653-7. Not eligible outcomes. [pmid: 12788170].
2905 Zafar N. Megakaryocytes in sentinel lymph node--a potential source for diagnostic error. Breast J. May–Jun. 2007;13(3):308-9. Case Reports. [pmid: 17461910].
2906 Zakaria S, Pantvaidya G, Ghosh K, et al. Paget’s disease of the breast: accuracy of preoperative assessment. Breast Cancer Res Treat. Apr. 2007;102(2):137-42. Not eligible target population. [pmid: 17028984].
2907 Zammit C, Coope R, Gomm JJ, et al. Fibroblast growth factor 8 is expressed at higher levels in lactating human breast and in breast cancer. Br J Cancer. Apr. 8. 2002;86(7):1097-103. Not eligible outcomes. [pmid: 11953856].
2908 Zamudio A. Finding solutions through the eyes of our patients. Fam Med. Jan. 2000;32(1):15-6. Case Reports. [pmid: 10645508].
2909 Zedeler K, Keiding N, Kamby C. Differential influence of prognostic factors on the occurrence of metastases at various anatomical sites in human breast cancer. Stat Med. Feb. 15. 1992;11(3):281-94. Not eligible target population. [pmid: 1319083].
2910 Zeidman SM, Rossitch EJ, Nashold BS Jr. Dorsal root entry zone lesions in the treatment of pain related to radiation-induced brachial plexopathy. J Spinal Disord. Feb. 1993;6(1):44-7. Case Reports. [pmid: 8382542].
2911 Zeillinger R, Kury F, Speiser P, et al. EGF-R and steroid receptors in breast cancer: a comparison with tumor grading, tumor size, lymph node involvement, and age. Clin Biochem. Jun. 1993;26(3):221-7. Not eligible outcomes. [pmid: 8392451].
2912 Zelis JJ, Sickle-Santanello BJ, Liang WC, et al. Do not contemplate invasive surgery for ductal carcinoma in situ. Am J Surg. Oct. 2002;184(4):348-9. Not eligible outcomes. [pmid: 12383899].
2913 Zhang GJ, Kimijima I, Abe R, et al. Correlation between the expression of apoptosis-related bcl-2 and p53 oncoproteins and the carcinogenesis and progression of breast carcinomas. Clin Cancer Res. Dec. 1997;3(12 Pt 1):2329-35. Not eligible outcomes. [pmid: 9815631].
2914 Zhang SY, Liu SC, Al-Saleem LF, et al. E2F-1: a proliferative marker of breast neoplasia. Cancer Epidemiol Biomarkers Prev. Apr. 2000;9(4):395-401. Not eligible outcomes. [pmid: 10794484].
2915 Zhang W, Yang YC, Zhang BN, et al. Biomarker analysis on breast ductal lavage cells in women with and without breast cancer. Int J Cancer. Jul. 15. 2006;119(2):359-64. Not eligible outcomes. [pmid: 16477639].
2916 Zhang X, Hashemi SS, Yousefi M, et al. Aberrant c-erbB2 expression in cell clusters overlying focally disrupted breast myoepithelial cell layers: a trigger or sign for emergence of more aggressive cell clones. Int J Biol Sci. 2008;4(5):259-69. Not eligible outcomes. [pmid: 18726004].
2917 Zhang Z, Yamashita H, Toyama T, et al. Semi-quantitative immunohistochemical analysis of aromatase expression in ductal carcinoma in situ of the breast. Breast Cancer Res Treat. Jul. 2002;74(1):47-53. Not eligible outcomes. [pmid: 12150452].
2918 Zhang Z, Yamashita H, Toyama T, et al. Estrogen receptor alpha mutation (A-to-G transition at nucleotide 908) is not found in different types of breast lesions from Japanese women. Breast Cancer. 2003;10(1):70-3. Not eligible outcomes. [pmid: 12525766].
2919 Zhao H, Morimoto T, Sasa M, et al. Immunohistochemical expression of uPA, PAI-1, cathepsin D and apoptotic cells in ductal carcinoma in situ of the breast. Breast Cancer. 2002;9(2):118-26. Not eligible outcomes. [pmid: 12016391].
2920 Zhou CJ, Zhang QH, Zhang TG, et al. Expression of ER, Ki-67 and CylinD1 in the Pre-cancerous Breast of Chinese Patients. Pathol Oncol Res. 2008. Oct. 22. Not eligible outcomes.
2921 Zhou Q, Fukushima P, DeGraff W, et al. Radiation and the Apo2L/TRAIL apoptotic pathway preferentially inhibit the colonization of premalignant human breast cells overexpressing cyclin D1. Cancer Res. May. 15. 2000;60(10):2611-5. Not eligible outcomes. [pmid: 10825131].
2922 Zhou X, Tan M, Stone Hawthorne V, et al. Activation of the Akt/mammalian target of rapamycin/4E-BP1 pathway by ErbB2 overexpression predicts tumor progression in breast cancers. Clin Cancer Res. Oct. 15. 2004;10(20):6779-88. Not eligible outcomes. [pmid: 15501954].
2923 Zhu J, Kurihara Y, Kanemaki Y, et al. Diagnostic accuracy of high-resolution MRI using a microscopy coil for patients with presumed DCIS following mammography screening. J Magn Reson Imaging. Jan. 2007;25(1):96-103. Not eligible outcomes. [pmid: 17154376].
2924 Zhu Q, Huang M, Chen N, et al. Ultrasound-guided optical tomographic imaging of malignant and benign breast lesions: initial clinical results of 19 cases. Neoplasia. Sep–Oct. 2003;5(5):379-88. Not eligible outcomes. [pmid: 14670175].
2925 Zhu Q, Tannenbaum S, Hegde P, et al. Noninvasive monitoring of breast cancer during neoadjuvant chemotherapy using optical tomography with ultrasound localization. Neoplasia. Oct. 2008;10(10):1028-40. Not eligible target population. [pmid: 18813360].
2926 Zitarelli J, Burkhart LL, Weiss SM. False negative breast biopsy for palpable mass. J Surg Oncol. Jan. 1993;52(1):61-3. Case Reports. [pmid: 8382756].
2927 Ziv Y, Shohat B, Wolloch Y, et al. Lymphocyte subpopulation before and after operation in patients with benign vs malignant breast disease. Panminerva Med. Apr–Jun. 1992;34(2):55-9. Not eligible target population. [pmid: 1328994].
2928 Zolota V, Gerokosta A, Melachrinou M, et al. Microvessel density, proliferating activity, p53 and bcl-2 expression in in situ ductal carcinoma of the breast. Anticancer Res. Jul–Aug. 1999;19(4B):3269-74. Not eligible outcomes. [pmid: 10652623].
2929 Zuiani C, Londero V, Bestagno A, et al. Proliferative high-risk lesions of the breast: contribution and limits of US-guided core biopsy. Radiol Med (Torino). Nov–Dec. 2005;110(5-6):589-602. Not eligible outcomes. [pmid: 16437044].
2930 Zuiani C, Mazzarella F, Londero V, et al. Stereotactic vacuum-assisted breast biopsy: results, follow-up and correlation with radiological suspicion. Radiol Med (Torino). Mar. 2007;112(2):304-17. Not eligible outcomes. [pmid: 17361368].
2931 Zujewski JA, Kamin L. Trial assessing individualized options for treatment for breast cancer: the TAILORx trial. Future Oncol. Oct. 2008;4(5):603-10. No associative hypothesis tested. [pmid: 18922117].
2932 Zunzunegui RG, Chung MA, Oruwari J, et al. Casting-type calcifications with invasion and high-grade ductal carcinoma in situ: a more aggressive disease. Arch Surg. May. 2003;138(5):537-40. Not eligible target population. [pmid: 12742959].
2933 Zytoon AA, Murakami K, El-Kholy MR, et al. Dual time point FDG-PET/CT imaging... Potential tool for diagnosis of breast cancer. Clin Radiol. Nov. 2008;63(11):1213-27. Not eligible exposure. [pmid: 18929039].