# Exact Search Strings

Initial search, April 17, 2008

Queries | Number of hits
"Raloxifene"[Mesh] AND "Carcinoma, Intraductal, Noninfiltrating" [Mesh] Limits: Entrez Date from 1990/01/01 to 2008/03/31, Humans, Female, Journal Article, English | 2
"Tamoxifen"[Mesh] AND "Carcinoma, Intraductal, Noninfiltrating" [Mesh] Limits: Entrez Date from 1990/01/01 to 2008/03/31, Humans, Female, Journal Article, English | 76
"Carcinoma, Lobular"[Mesh] AND "Carcinoma, Intraductal, Noninfiltrating"[Mesh] Limits: Entrez Date from 1990/01/01 to 2008/03/31, Humans, Female, Journal Article, English | 240
"Prevalence"[Mesh] AND "Carcinoma, Intraductal, Noninfiltrating" [Mesh] Limits: Entrez Date from 1990/01/01 to 2008/03/31, Humans, Female, Journal Article, English | 18
("Carcinoma, Intraductal, Noninfiltrating/epidemiology"[Mesh] OR "Carcinoma, Intraductal, Noninfiltrating/genetics"[Mesh] OR "Carcinoma, Intraductal, Noninfiltrating/mortality"[Mesh] OR "Carcinoma, Intraductal, Noninfiltrating/prevention and control" [Mesh] OR "Carcinoma, Intraductal, Noninfiltrating/radiotherapy" [Mesh] OR "Carcinoma, Intraductal, Noninfiltrating/surgery"[Mesh] OR "Carcinoma, Intraductal, Noninfiltrating/therapy"[Mesh] OR "Carcinoma, Intraductal, Noninfiltrating/ultrasonography"[Mesh]) Limits: Entrez Date from 1990/01/01 to 2008/03/31, Humans, Female, Journal Article, English | 1356
"Carcinoma, Intraductal, Noninfiltrating"[Mesh] prospective cohort Limits: Humans, Female, English, All Adult: 19+ years | 24
Search "Carcinoma, Intraductal, Noninfiltrating"[Mesh] AND ("Prognosis"[Mesh] OR "Outcome and Process Assessment (Health Care)"[Mesh] OR "Treatment Outcome"[Mesh]) Limits: Humans, Female, Journal Article, English, All Adult: 19+ years | 503
Search "Carcinoma, Intraductal, Noninfiltrating"[Mesh] AND ("Neoplasm Recurrence, Local"[Mesh] OR "Neoplasm Metastasis"[Mesh]) Limits: Humans, Female, Journal Article, English, All Adult: 19+ years | 744
We extended a literature search with key words to identify relevant studies published from 1966 (April 17, 2008)
"Ductal carcinoma in situ" Limits: Humans, Female, Randomized Controlled Trial, English, All Adult: 19+ years | 32
DCIS Limits: Humans, Female, Randomized Controlled Trial, English, All Adult: 19+ years | 39
"ductal carcinoma in situ" Limits: Humans, Female, Journal Article, English, All Adult: 19+ years | 1266
"ductal carcinoma in situ" | 2677
DCIS NOT review NOT case reports Limits: Humans, Female, Journal Article, English, All Adult: 19+ years | 2133
"Magnetic Resonance Imaging"[Mesh]AND "Carcinoma, Intraductal, Noninfiltrating"[Mesh] Limits: Humans, Female, Journal Article, English | 104
"Mass Screening"[Mesh] AND "Carcinoma, Intraductal, Noninfiltrating"[Mesh]Limits: Humans, Female, Journal Article, English | 97
"Aromatase Inhibitors"[Mesh] AND "Carcinoma, Intraductal, Noninfiltrating"[Mesh] Limits: Humans, Female, Randomized Controlled Trial, English | 0
"Aromatase Inhibitors"[Mesh]AND "Carcinoma, Intraductal, Noninfiltrating"[Mesh] | 11
NOT review "Aromatase Inhibitors"[Mesh] AND "Carcinoma, Intraductal, Noninfiltrating"[Mesh] Limits: Clinical Trial, Phase II, Clinical Trial, Phase III, Clinical Trial, Phase IV | 0
"Carcinoma, Intraductal, Noninfiltrating"[Mesh] AND "Genetic Predisposition to Disease"[Mesh]Limits: Humans, Female, Journal Article, English | 22
"Multivariate Analysis"[Mesh] AND "Cohort Studies"[Mesh] AND "Carcinoma, Intraductal, Noninfiltrating"[Mesh]Limits: Humans, Female, English | 20
"Hormone Replacement Therapy"[Mesh] AND non invasive cancer Limits: Humans, Female, Randomized Controlled Trial, English, All Adult: 19+ years | 7
"Hormone Replacement Therapy"[Mesh] AND in situ Limits: Humans, Female, Randomized Controlled Trial, English, All Adult: 19+ years | 2
"Hormone Replacement Therapy"[Mesh] AND breast cancer Limits: Humans, Female, Randomized Controlled Trial, English, All Adult: 19+ years | 67
"Hormone Replacement Therapy"[Mesh] AND breast cancer Limits: Humans, Female, Randomized Controlled Trial, English, All Adult: 19+ years AND "Carcinoma, Intraductal, Noninfiltrating"[Mesh] | 0
Aminoglutethimide OR Anastrozole OR Letrozole OR Vorozole OR Formestane OR Testolactone OR Exemestane AND breast Limits: Humans, Female, Randomized Controlled Trial, English, All Adult: 19+ years | 195
("Carcinoma, Intraductal, Noninfiltrating"[Mesh] OR ("Carcinoma, Intraductal, Noninfiltrating/radiotherapy"[Mesh] OR "Carcinoma, Intraductal, Noninfiltrating/surgery"[Mesh] OR "Carcinoma, Intraductal, Noninfiltrating/therapy"[Mesh]))NOT ("Carcinoma, Intraductal, Noninfiltrating/radiotherapy"[Mesh] OR "Carcinoma, Intraductal, Noninfiltrating/surgery"[Mesh] OR "Carcinoma, Intraductal, Noninfiltrating/therapy"[Mesh])) AND "Prospective Studies"[Mesh] Limits: Humans, Female, Journal Article, English, All Adult: 19+ years | 57
("Carcinoma, Intraductal, Noninfiltrating"[Mesh] OR ("Carcinoma, Intraductal, Noninfiltrating/radiotherapy"[Mesh] OR "Carcinoma, Intraductal, Noninfiltrating/surgery"[Mesh] OR "Carcinoma, Intraductal, Noninfiltrating/therapy"[Mesh]))NOT ("Carcinoma, Intraductal, Noninfiltrating/radiotherapy"[Mesh] OR "Carcinoma, Intraductal, Noninfiltrating/surgery"[Mesh] OR "Carcinoma, Intraductal, Noninfiltrating/therapy"[Mesh]))Limits: Humans, Female, Journal Article, English, All Adult: 19+ years | 1682
Sentinel Node Biopsy AND "Carcinoma, Intraductal, Noninfiltrating"[Mesh] Limits: Humans, Female, Journal Article, English, All Adult: 19+ years | 72
Additional search, July 22, 2008
"Sentinel Lymph Node Biopsy"[Mesh] AND "Carcinoma, Intraductal, Noninfiltrating"[Mesh]Limits: Humans, Female, Journal Article, English, All Adult: 19+ years
Additional search, July 29, 2008
Related Articles for PubMed (Select 15804465) | 1359
Select 77 document(s) | 77
Additional search, July 30, 2008
"Breast"[Mesh] AND "Carcinoma in Situ"[Mesh] NOT lobular NOT Case-Reports Limits: Humans, Female, Journal Article, English, All Adult: 19+ years | 177
Additional search, July 31 | 513
"Carcinoma, Intraductal, Noninfiltrating"[Mesh] AND "Breast"[Mesh] Limits: Humans, Female, Journal Article, English, All Adult: 19+ years
Search "Breast"[Mesh] AND "Carcinoma in Situ"[Mesh] Limits: Humans, Female, Journal Article, English, All Adult: 19+ years | 320
Additional search, August 6, 2008
Select 87 document(s) | 87
Related Articles for PubMed (Select 8978410) AND ductal carcinoma in situ Limits: Humans, Female, Journal Article, English, All Adult: 19+ years | 163
Related Articles for PubMed (Select 8978410) | 1457
Related Articles for PubMed (Select 18760400 AND sentinel Limits: Humans, Female, Journal Article, English, All
Adult: 19+ years 28 Additional search, September 10, 2008
MRI AND DCIS AND bilateral Limits: Humans, Female, English | 10
MRI AND DCIS AND multifocal Limits: Humans, Female, English | 7
diagnostic breast MR imaging AND DCIS NOT review Limits: Humans, Female, Journal Article, English, All Adult: 19+ years | 43
Updated search, January 30, 2009
DCIS Limits: Entrez Date from 2008/8/01 to 2009/3/31 | 121
"Carcinoma, Ductal, Breast"[Mesh] Limits: Entrez Date from 2008/8/01 to 2009/3/31 | 133
"Carcinoma, Intraductal, Noninfiltrating"[Mesh] Limits: Entrez Date from 2008/8/01 to 2009/3/31 | 57

MeSH HEADING: CARCINOMA, INTRADUCTAL, NONINFILTRATING

SCOPE: A noninvasive (noninfiltrating) carcinoma of the breast characterized by a proliferation of malignant epithelial cells confined to the mammary ducts or lobules, without light-microscopy evidence of invasion through the basement membrane into the surrounding stroma.

NOTE: intraductal refers to mammary ducts only; do not confuse entry term CARCINOMA, INTRADUCTAL with CARCINOMA, DUCTAL; CARCINOMA, DUCTAL, BREAST; or CARCINOMA, PANCREATIC DUCTAL; coordinate IM with BREAST NEOPLASMS (IM)

YEAR of ENTRY: 94; was CARCINOMA, DUCTAL 1963–93

SEARCH NOTE: use CARCINOMA, INTRADUCTAL, NONINFILTRATING to search CARCINOMA, DUCTAL 1966–93

REFERENCES:

Used For:

carcinoma, intraductal, noninfiltrating

carcinoma, intraductal

carcinomas, intraductal

intraductal carcinoma

intraductal carcinomas

dcis

ductal carcinoma in situ

intraductal carcinoma, noninfiltrating

carcinoma, noninfiltrating intraductal

carcinomas, noninfiltrating intraductal

intraductal carcinomas, noninfiltrating

noninfiltrating intraductal carcinoma

noninfiltrating intraductal carcinomas

We conducted an additional expert search to compared sensitivity of different search strategies in Medline via PubMed and Ovid. The librarian searched for epidemiologic studies and eliminated reviews, case reports, comments, or letters. She first limited the results to 2007–2009, then limited to 2008–2008 to see the difference in retrieval (340 vs. 154) She included a fairly broad range of articles using the floating subheading for/ep (epidemiology), the explosion of "epidemiologic study characteristics" and the explosion of "epidemiologic research design." She also included subject headings for incidence and prevalence. She used the preferred subject heading "carcinoma, intraductal, noninfiltrating" but also also searched for text words DCIS and "ductal carcinoma in situ." Restriction to female and to breast eliminated three citations.

>Ovid Technologies, Inc. Email Service
>Search for: 18 and 16
>Results: 1–151
Database: Ovid MEDLINE(R) <1950 to February Week 1 2009>
Search Strategy:
1 | ductal carcinoma in situ.mp. (2729)
2 | exp carcinoma, intraductal, noninfiltrating/(6452)
3 | dcis.mp. (1916)
4 | ep.fs. (828160)
5 | exp epidemiologic study characteristics/(1359358)
6 | exp epidemiologic research design/(565747)
7 | exp incidence/(120925)
8 | exp prevalence/(118994)
9 | 1 or 3 or 2 (8286)
10 | 8 or 6 or 4 or 7 or 5 (2328255)
11 | 10 and 9 (2603)
12 | limit 11 to (english language and humans and yr="2007 – 2009") (340)
13 | limit 12 to journal article (325)
14 | limit 12 to (case reports or comment or editorial or letter or "review") (39)
15 | 13 not 14 (300)
16 | limit 15 to yr="2008 – 2009" (154)
17 | exp breast diseases/or exp breast/or breast.mp. (246385)
18 | 17 and 16 (151)
19 | from 18 keep 1–151 (151)

After discarding duplicated 78 articles were added to the library and reviewed for eligibility status.