# Appendixes

Appendix A Exact Search Strings

Appendix B List of Excluded Studies

Appendix C Technical Expert Panel Members and Affiliation

Appendix D Analytical Framework

Appendix E Abstraction Forms

Appendix F Evidence Tables