# List of Acronyms/Abbreviations

AHRQ: Agency for Healthcare Research and Quality
AJCC: American Joint Committee on Cancer
ALND: Axillary lymph node dissection
APBI: Accelerated partial breast irradiation
BCS: Breast conserving surgery
BMI: Body mass index
CI: Confidence interval
CORE: Continuing Outcomes Relevant to Evista
DCIS: Ductal carcinoma in situ
DCISM: Ductal carcinoma in situ with microinvasion
EBRT: External beam radiotherapy
EORTC: European Organization for Research and Treatment of Cancer
ER: Estrogen receptors
GRADE: Grading of Recommendations Assessment, Development, and Evaluation
HR: Hazard ratio
HRT: Hormone replacement therapy
IBSN: International Breast Cancer Screening Network
IHC: Immunohistochemistry
IORT: Intraoperative radiotherapy
LCIS: Lobular carcinoma in situ
MOOSE: Meta-analysis of Observational Studies in Epidemiology
MORE: Multiple Outcomes of Raloxifene Evaluation
MRI: Magnetic resonance imaging
NBSS: National Breast Screening Study
NCI: National Cancer Institute
NIH: National Institutes of Health
NSABP: National Surgical Adjuvant Breast and Bowel Project
OCOG: Ontario Clinical Oncology Group
OR: Odds ratio
PR: Progesterone receptor
QUORUM: Quality of Reporting of Meta-analyses
RCT: Randomized controlled trial
RR: Relative risk
RT: Radiation therapy
SEER: Surveillance Epidemiology and Ends Results
SERM: Selective estrogen receptor modulator
SLN: Sentinel lymph node
SLNB: Sentinel lymph node biopsy
STAR: Study of Tamoxifen and Raloxifene
TEP: Technical expert panel
TROG: Trans-Tasman Radiation Oncology Group
WHO: World Health Organization