# Acknowledgments

We would like to thank our technical expert panel members (Amy Degnim, M.D.; Stephen Edge, M.D., F.A.C.S.; Jay Harris, M.D.; Kelly Hunt, M.D., F.A.C.S.; Karla Kerlikowske, M.S., M.D.; Lee Tan, M.D.; and Eric Winer, M.D.) for their scientific and clinical input; Shilpa Amin, M.D., M.Bsc., FAAFP, our Task Order Officer from AHRQ and Stephanie Chang, M.D., Medical Officer at AHRQ, for their guidance throughout the project; and Carmen Allegra, M.D., for his consultation. We also want to thank Chip Cody, M.D. and Tracy Onega, Ph.D. for reviewing and commenting on the draft.

We want to thank the librarian, Judith Stanke, for her contributions to the literature search; Shi-Yi Wang, M.D., Zhihua Bian, candidate for MS in biostatistics, and Emily Wang, M.P.H. candidate, for abstracting articles and preparing tables; Karen Rashke, Nancy Russell, and Rebecca Schultz for gathering articles and helping to format tables; and Marilyn Eells for editing and formatting the report.