# References and Included Studies

(Note that there are separate sets of references in some of the appendixes. The reference numbers there are different from those in the text of the report.)

1 Johnell O, Kanis JA. An estimate of the worldwide prevalence, mortality and disability associated with hip fracture. Osteoporosis International. Nov. 2004;15(11):897-902. [pmid: 15490120].
2 National Center for Health Statistics. Trends in Health and Aging. US Department of Health and Human Services. 2006.
3 Aschkenasy MT, Rothenhaus TC. Trauma and falls in the elderly. Emergency Medicine Clinics of North America. May. 2006;24(2):413-32. [pmid: 16584964].
4 Marks R, Allegrante JP, Ronald MacKenzie C, et al. Hip fractures among the elderly: causes, consequences and control. Ageing Research Reviews. Jan. 2003;2(1):57-93. [pmid: 12437996].
5 Melton LJ 3rd. Epidemiology of hip fractures: implications of the exponential increase with age. Bone. Mar. 1996;18(3 Suppl):121S-5S. [pmid: 8777076].
6 Zuckerman JD. Hip fracture.[see comment]. New England Journal of Medicine. Jun. 6. 1996;334(23):1519-25. [pmid: 8618608].
7 Cummings SR, Melton LJ. Epidemiology and outcomes of osteoporotic fractures.[see comment]. Lancet. May. 18. 2002;359(9319):1761-7. [pmid: 12049882].
8 Richmond J, Aharonoff GB, Zuckerman JD, et al. Mortality risk after hip fracture. 2003. Journal of Orthopaedic Trauma. Sep. 2003;17(8 Suppl):S2-5. [pmid: 14696770].
9 Leibson CL, Tosteson ANA, Gabriel SE, et al. Mortality, disability, and nursing home use for persons with and without hip fracture: a population-based study. Journal of the American Geriatrics Society. Oct. 2002;50(10):1644-50. [pmid: 12366617].
10 Roche JJW, Wenn RT, Sahota O, et al. Effect of comorbidities and postoperative complications on mortality after hip fracture in elderly people: prospective observational cohort study. BMJ. Dec. 10. 2005;331(7529):1374. [pmid: 16299013].
11 Endo Y, Aharonoff GB, Zuckerman JD, et al. Gender differences in patients with hip fracture: a greater risk of morbidity and mortality in men.[see comment]. Journal of Orthopaedic Trauma. Jan. 2005;19(1):29-35. [pmid: 15668581].
12 Robbins JA, Biggs ML, Cauley J. Adjusted mortality after hip fracture: From the cardiovascular health study. Journal of the American Geriatrics Society. Dec. 2006;54(12):1885-91. [pmid: 17198494].
13 Koval KJ, Skovron ML, Aharonoff GB, et al. Predictors of functional recovery after hip fracture in the elderly. Clinical Orthopaedics & Related Research. Mar. 1998;(348):22-8. [pmid: 9553529].
14 Koval KJ, Skovron ML, Aharonoff GB, et al. Ambulatory ability after hip fracture. A prospective study in geriatric patients. Clinical Orthopaedics & Related Research. Jan. 1995;(310):150-9. [pmid: 7641432].
15 Chrischilles EA, Butler CD, Davis CS, et al. A model of lifetime osteoporosis impact.[erratum appears in Arch Intern Med 1922 Mar;152(3):655]. Archives of Internal Medicine. Oct. 1991;151(10):2026-32. [pmid: 1929691].
16 Jaglal SB, Sherry PG, Schatzker J. The impact and consequences of hip fracture in Ontario. Canadian Journal of Surgery. Apr. 1996;39(2):105-11.
17 Michelson JD, Myers A, Jinnah R, et al. Epidemiology of hip fractures among the elderly. Risk factors for fracture type. Clinical Orthopaedics & Related Research. Feb. 1995;(311):129-35. [pmid: 7634567].
18 Koval KJ, Aharonoff GB, Rokito AS, et al. Patients with femoral neck and intertrochanteric fractures. Are they the same?. Clinical Orthopaedics & Related Research. Sep. 1996;(330):166-72. [pmid: 8804287].
19 Forte ML, Virnig BA, Kane RL, et al. Geographic variation in device use for intertrochanteric hip fractures.[see comment]. Journal of Bone & Joint Surgery - American Volume. Apr. 2008;90(4):691-9.
20 Bosch U, Schreiber T, Krettek C. Reduction and fixation of displaced intracapsular fractures of the proximal femur. Clinical Orthopaedics & Related Research. Jun. 2002;(399):59-71. [pmid: 12011695].
21 Lorich DG, Geller DS, Nielson JH. Osteoporotic pertrochanteric hip fractures: management and current controversies. Instructional Course Lectures. 2004;53:441-54. [pmid: 15116633].
22 West S, King V, Carey TS, et al. Systems to rate the strength of scientific evidence. Rockville, MD. Prepared by the Research Triangle Institute-University of North Carolina. Evidence-based Practice Center under Contract No. 290-97-0011; Evidence Report/Technology Assessment No. 47, AHRQ Publication No. 02-E016. April. 2002.
23 Atkins D, Best D, Briss PA, et al. Grading quality of evidence and strength of recommendations. BMJ. Jun. 19. 2004;328(7454):1490. [pmid: 15205295].
24 Rehnberg L, Olerud C. Fixation of femoral neck fractures. Comparison of the Uppsala and von Bahr screws. Acta Orthopaedica Scandinavica. Oct. 1989;60(5):579-84. [pmid: 2690558].
25 Paus A, Gjengedal E, Hareide A, et al. Dislocated fractures of the femoral neck treated with von Bahr screws or hip compression screw. Results of a prospective, randomized study. Journal of the Oslo City Hospitals. May–Jun. 1986;36(5–6):55-61. [pmid: 3761061].
26 Rogmark C, Johnell O. Primary arthroplasty is better than internal fixation of displaced femoral neck fractures: a meta-analysis of 14 randomized studies with 2,289 patients.[see comment]. Acta Orthopaedica. Jun. 2006;77(3):359-67. [pmid: 16819672].
27 Miyamoto RG, Kaplan KM, Levine BR, et al. Surgical management of hip fractures: an evidence-based review of the literature. I: femoral neck fractures. Journal of the American Academy of Orthopaedic Surgeons. Oct. 2008;16(10):596-607. [pmid: 18832603].
28 Bhandari M, Devereaux PJ, Swiontkowski MF, et al. Internal fixation compared with arthroplasty for displaced fractures of the femoral neck. A meta-analysis. Journal of Bone & Joint Surgery - American Volume. Sep. 2003;85-A(9):1673-81.
29 Parker MJ, Handoll HHG. Extramedullary fixation implants and external fixators for extracapsular hip fractures in adults.[update of Cochrane Database Syst Rev. 2002;(4):CD000339; PMID: 12519541]. Cochrane Database of Systematic Reviews. 2006;(1):CD000339. [pmid: 16437422].
30 Parker MJ, Handoll HHG. Gamma and other cephalocondylic intramedullary nails versus extramedullary implants for extracapsular hip fractures.[update in Cochrane Database Syst Rev. 2005;(4):CD000093; PMID: 16235272][update of Cochrane Database Syst Rev. 2002;(4):CD000093; PMID: 12519535]. Cochrane Database of Systematic Reviews. 2004;(1):CD000093. [pmid: 14973946].
31 Kregor PJ, Obremskey WT, Kreder HJ, et al. Unstable pertrochanteric femoral fractures. Journal of Orthopaedic Trauma. Jan. 2005;19(1):63-6. [pmid: 15668589].
32 Kaplan K, Miyamoto R, Levine BR, et al. Surgical management of hip fractures: an evidence-based review of the literature. II: intertrochanteric fractures. Journal of the American Academy of Orthopaedic Surgeons. Nov. 2008;16(11):665-73. [pmid: 18978289].
33 Koval KJ, Skovron ML, Polatsch D, et al. Dependency after hip fracture in geriatric patients: a study of predictive factors. Journal of Orthopaedic Trauma. 1996;10(8):531-5. [pmid: 8915914].
34 Magaziner J, Hawkes W, Hebel JR, et al. Recovery from hip fracture in eight areas of function.[see comment]. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. Sep. 2000;55(9):M498-507.
35 Holt G, Smith R, Duncan K, et al. Epidemiology and outcome after hip fracture in the under 65s-evidence from the Scottish Hip Fracture Audit. Injury. Oct. 2008;39(10):1175-81. [pmid: 18703186].
36 Ahn H, Bhandari M, Schemitsch EH. An evidence-based approach to the adoption of new technology. Journal of Bone & Joint Surgery - American Volume. May. 2009;91(Suppl 3):95-8.
37 Simunovic N, Sprague S, Bhandari M. Methodological issues in systematic reviews and meta-analyses of observational studies in orthopaedic research. Journal of Bone & Joint Surgery - American Volume. May. 2009;91(Suppl 3):87-94.
38 Sprague S, Matta JM, Bhandari M, et al. Multicenter collaboration in observational research: improving generalizability and efficiency. Journal of Bone & Joint Surgery - American Volume. May. 2009;91(Suppl 3):80-6.
39 Morshed S, Tornetta P 3rd, Bhandari M. Analysis of observational studies: a guide to understanding statistical methods. Journal of Bone & Joint Surgery - American Volume. May. 2009;91(Suppl 3):50-60.
40 Poolman RW, Swiontkowski MF, Fairbank JCT, et al. Outcome instruments: rationale for their use. Journal of Bone & Joint Surgery - American Volume. May. 2009;91(Suppl 3):41-9.
41 Zlowodzki M, Bhandari M. Outcome measures and implications for sample-size calculations. Journal of Bone & Joint Surgery - American Volume. May. 2009;91(Suppl 3):35-40.
42 Bryant DM, Willits K, Hanson BP. Principles of designing a cohort study in orthopaedics. Journal of Bone & Joint Surgery - American Volume. May. 2009;91(Suppl 3):10-4.
43 Hoppe DJ, Schemitsch EH, Morshed S, et al. Hierarchy of evidence: where observational studies fit in and why we need them. Journal of Bone & Joint Surgery - American Volume. May. 2009;91(Suppl 3):2-9.
44 Oude Voshaar RC, Banerjee S, Horan M, et al. Fear of falling more important than pain and depression for functional recovery after surgery for hip fracture in older people. Psychological Medicine. Nov. 2006;36(11):1635-45. [pmid: 16863598].
45 Mjorud J, Skaro O, Solhaug JH, et al. A randomised study in all cervical hip fractures osteosynthesis with Hansson hook-pins versus AO-screws in 199 consecutive patients followed for two years. Injury. Aug. 2006;37(8):768-77. [pmid: 16476431].
46 Miedel R, Ponzer S, Tornkvist H, et al. The standard Gamma nail or the Medoff sliding plate for unstable trochanteric and subtrochanteric fractures. A randomised, controlled trial. Journal of Bone & Joint Surgery - British Volume. Jan. 2005;87(1):68-75.
47 Baumgaertner MR, Curtin SL, Lindskog DM. Intramedullary versus extramedullary fixation for the treatment of intertrochanteric hip fractures. Clinical Orthopaedics & Related Research. Mar. 1998;(348):87-94. [pmid: 9553538].
48 Heetveld MJ, Raaymakers ELFB, Luitse JSK, et al. Rating of internal fixation and clinical outcome in displaced femoral neck fractures: a prospective multicenter study. Clinical Orthopaedics & Related Research. Jan. 2007;454:207-13. [pmid: 17031315].
49 Heetveld MJ, Raaymakers ELFB, Luitse JSK, et al. Femoral neck fractures: can physiologic status determine treatment choice?. Clinical Orthopaedics & Related Research. Aug. 2007;461:203-12. [pmid: 17414163].
50 Shabat S, Mann G, Nyska M, et al. Scoring systems to evaluate elderly patients with hip fractures. Disability & Rehabilitation. Sep 30-Oct 15. 2005;27(18–19):1041-4. [pmid: 16278173].
51 Orwig DL, Chan J, Magaziner J. Hip fracture and its consequences: differences between men and women. Orthopedic Clinics of North America. Oct. 2006;37(4):611-22. [pmid: 17141019].
52 Hawkes WG, Wehren L, Orwig D, et al. Gender differences in functioning after hip fracture. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. May. 2006;61(5):495-9.
53 Goulding M, Rogers M, Smith S. Public Health and Aging: Trends in Aging - United States and Worldwide. MMWR Weekly. February. 14. 2003;52(06):101-6.
54 Chang KP, Center JR, Nguyen TV, et al. Incidence of hip and other osteoporotic fractures in elderly men and women: Dubbo Osteoporosis Epidemiology Study. Journal of Bone & Mineral Research. Apr. 2004;19(4):532-6. [pmid: 15005838].
55 Haentjens P, Johnell O, Kanis JA, et al. Evidence from data searches and life-table analyses for gender-related differences in absolute risk of hip fracture after Colles' or spine fracture: Colles' fracture as an early and sensitive marker of skeletal fragility in white men. Journal of Bone & Mineral Research. Dec. 2004;19(12):1933-44. [pmid: 15537435].
56 French DD, Campbell R, Spehar A, et al. Outpatient medications and hip fractures in the US: a national veterans study. Drugs & Aging. 2005;22(10):877-85. [pmid: 16245960].
57 Katelaris AG, Cumming RG. Health status before and mortality after hip fracture. American Journal of Public Health. Apr. 1996;86(4):557-60. [pmid: 8604790].
58 Craig NJA, Maffulli N. Subtrochanteric fractures: current management options. Disability & Rehabilitation. Sep 30-Oct 15. 2005;27(18–19):1181-90. [pmid: 16278187].
59 Gallagher JC, Melton LJ, Riggs BL, et al. Epidemiology of fractures of the proximal femur in Rochester, Minnesota. Clinical Orthopaedics & Related Research. Jul–Aug. 1980;(150):163-71. [pmid: 7428215].
60 Lykke N, Lerud PJ, Stromsoe K, et al. Fixation of fractures of the femoral neck. A prospective, randomised trial of three Ullevaal hip screws versus two Hansson hook-pins.[see comment]. Journal of Bone & Joint Surgery - British Volume. Apr. 2003;85(3):426-30.
61 Elmerson S, Sjostedt A, Zetterberg C. Fixation of femoral neck fracture. A randomized 2-year follow-up study of hook pins and sliding screw plate in 222 patients. Acta Orthopaedica Scandinavica. Dec. 1995;66(6):507-10. [pmid: 8553816].
62 Shah AK, Eissler J, Radomisli T. Algorithms for the treatment of femoral neck fractures. Clinical Orthopaedics & Related Research. Jun. 2002;(399):28-34. [pmid: 12011691].
63 Rodriguez-Merchan EC. Displaced intracapsular hip fractures: hemiarthroplasty or total arthroplasty?. Clinical Orthopaedics & Related Research. Jun. 2002;(399):72-7. [pmid: 12011696].
64 Bhandari M, Devereaux PJ, Tornetta P 3rd, et al. Operative management of displaced femoral neck fractures in elderly patients. An international survey. Journal of Bone & Joint Surgery - American Volume. Sep. 2005;87(9):2122-30.
65 Lu-Yao GL, Keller RB, Littenberg B, et al. Outcomes after displaced fractures of the femoral neck. A meta-analysis of one hundred and six published reports. Journal of Bone & Joint Surgery - American Volume. Jan. 1994;76(1):15-25.
66 Masson M, Parker MJ, Fleischer S. Internal fixation versus arthroplasty for intracapsular proximal femoral fractures in adults.[update in Cochrane Database Syst Rev. 2006;(4):CD001708; PMID: 17054139]. Cochrane Database of Systematic Reviews. 2003;(2):CD001708. [pmid: 12804413].
67 Anglen JO, Weinstein JN. American Board of Orthopaedic Surgery Research C. Nail or plate fixation of intertrochanteric hip fractures: changing pattern of practice. A review of the American Board of Orthopaedic Surgery Database.[see comment]. Journal of Bone & Joint Surgery - American Volume. Apr. 2008;90(4):700-7.
68 Bedi A, Toan Le T. Subtrochanteric femur fractures. Orthopedic Clinics of North America. Oct. 2004;35(4):473-83. [pmid: 15363922].
69 Sadowski C, Lubbeke A, Saudan M, et al. Treatment of reverse oblique and transverse intertrochanteric fractures with use of an intramedullary nail or a 95 degrees screw-plate: a prospective, randomized study. Journal of Bone & Joint Surgery - American Volume. Mar. 2002;84-A(3):372-81.
70 Palm H, Jacobsen S, Krasheninnikoff M, et al. Influence of surgeon's experience and supervision on re-operation rate after hip fracture surgery. Injury. Jul. 2007;38(7):775-9. [pmid: 17049523].
71 Bozic KJ, Jacobs JJ. Technology assessment and adoption in orthopaedics: lessons learned.[comment]. Journal of Bone & Joint Surgery - American Volume. Apr. 2008;90(4):689-90.
72 Parker MJ, Handoll HHG. Intramedullary nails for extracapsular hip fractures in adults.[update of Cochrane Database Syst Rev. 2005;(2):CD004961; PMID: 15846737]. Cochrane Database of Systematic Reviews. 2006;3:CD004961. [pmid: 16856070].
73 Palm H, Jacobsen S, Sonne-Holm S, et al. Integrity of the lateral femoral wall in intertrochanteric hip fractures: an important predictor of a reoperation.[see comment]. Journal of Bone & Joint Surgery - American Volume. Mar. 2007;89(3):470-5.
74 Baumgaertner MR, Curtin SL, Lindskog DM, et al. The value of the tip-apex distance in predicting failure of fixation of peritrochanteric fractures of the hip.[see comment]. Journal of Bone & Joint Surgery - American Volume. Jul. 1995;77(7):1058-64.
75 Kyle RF, Cabanela ME, Russell TA, et al. Fractures of the proximal part of the femur. Instructional Course Lectures. 1995;44:227-53. [pmid: 7797861].
76 Beaupre LA, Cinats JG, Jones CA, et al. Does functional recovery in elderly hip fracture patients differ between patients admitted from long-term care and the community?. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. Oct. 2007;62(10):1127-33.
77 Siu AL, Boockvar KS, Penrod JD, et al. Effect of inpatient quality of care on functional outcomes in patients with hip fracture. Medical Care. Sep. 2006;44(9):862-9. [pmid: 16932138].
78 Stolee P, Poss J, Cook RJ, et al. Risk factors for hip fracture in older home care clients. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. Mar. 2009;64(3):403-10.
79 Devereaux PJ, Choi PTL, Lacchetti C, et al. A systematic review and meta-analysis of studies comparing mortality rates of private for-profit and private not-for-profit hospitals.[see comment]. CMAJ Canadian Medical Association Journal. May. 28. 2002;166(11):1399-406. [pmid: 12054406].
80 Shiga T, Wajima Zi, Ohe Y. Is operative delay associated with increased mortality of hip fracture patients? Systematic review, meta-analysis, and meta- regression. Canadian Journal of Anaesthesia. Mar. 2008;55(3):146-54. [pmid: 18310624].
81 Radcliff TA, Henderson WG, Stoner TJ, et al. Patient risk factors, operative care, and outcomes among older community-dwelling male veterans with hip fracture. Journal of Bone & Joint Surgery - American Volume. Jan. 2008;90(1):34-42.
82 Hannan EL, Magaziner J, Wang JJ, et al. Mortality and locomotion 6 months after hospitalization for hip fracture: risk factors and risk-adjusted hospital outcomes. JAMA. Jun. 6. 2001;285(21):2736-42. [pmid: 11386929].
83 Applegate WB, Miller ST, Graney MJ, et al. A randomized, controlled trial of a geriatric assessment unit in a community rehabilitation hospital. New England Journal of Medicine. May. 31. 1990;322(22):1572-8. [pmid: 2186276].
84 Kennie DC, Reid J, Richardson IR, et al. Effectiveness of geriatric rehabilitative care after fractures of the proximal femur in elderly women: a randomised clinical trial. BMJ. Oct. 29. 1988;297(6656):1083-6. [pmid: 3143436].
85 Kane RL, Finch M, Blewett L, et al. Use of post-hospital care by Medicare patients. Journal of the American Geriatrics Society. Mar. 1996;44(3):242-50. [pmid: 8600191].
86 Scottish Intercollegiate Guidelines Network. SIGN. Available at: SIGN, http://www.sign.ac.uk/methodology/filters.html#random. Accessed Feb 12, 2009.
87 Furlan AD, Irvin E, Bombardier C. Limited search strategies were effective in finding relevant nonrandomized studies. Journal of Clinical Epidemiology. Dec. 2006;59(12):1303-11. [pmid: 17098573].
88 Wilczynski NL, Haynes RB, Lavis JN, et al. Optimal search strategies for detecting health services research studies in MEDLINE. CMAJ Canadian Medical Association Journal. Nov. 9. 2004;171(10):1179-85. [pmid: 15534310].
89 Bhandari M, Tornetta Pr, Ellis T, et al. Hierarchy of evidence: differences in results between non-randomized studies and randomized trials in patients with femoral neck fractures. Archives of Orthopaedic & Trauma Surgery. Jan. 2004;124(1):10-6. [pmid: 14576955].
90 Majumdar SR, Beaupre LA, Johnston DWC, et al. Lack of association between mortality and timing of surgical fixation in elderly patients with hip fracture: results of a retrospective population-based cohort study.[see comment]. Medical Care. Jun. 2006;44(6):552-9. [pmid: 16708004].
91 Papasimos S, Koutsojannis CM, Panagopoulos A, et al. A randomised comparison of AMBI, TGN and PFN for treatment of unstable trochanteric fractures. Archives of Orthopaedic & Trauma Surgery. Sep. 2005;125(7):462-8. [pmid: 16059696].
92 Utrilla AL, Reig JS, Munoz FM, et al. Trochanteric gamma nail and compression hip screw for trochanteric fractures: a randomized, prospective, comparative study in 210 elderly patients with a new design of the gamma nail. Journal of Orthopaedic Trauma. Apr. 2005;19(4):229-33. [pmid: 15795570].
93 Mattsson P, Larsson S. Unstable trochanteric fractures augmented with calcium phosphate cement. A prospective randomized study using radiostereometry to measure fracture stability. Scandinavian Journal of Surgery: SJS. 2004;93(3):223-8. [pmid: 15544079].
94 Pajarinen J, Lindahl J, Savolainen V, et al. Femoral shaft medialisation and neck-shaft angle in unstable pertrochanteric femoral fractures. International Orthopaedics. Dec. 2004;28(6):347-53. [pmid: 15597171].
95 Moroni A, Faldini C, Pegreffi F, et al. HA-coated screws decrease the incidence of fixation failure in osteoporotic trochanteric fractures. Clinical Orthopaedics & Related Research. Aug. 2004;(425):87-92. [pmid: 15292792].
96 Peyser A, Weil YA, Brocke L, et al. A prospective, randomised study comparing the percutaneous compression plate and the compression hip screw for the treatment of intertrochanteric fractures of the hip. Journal of Bone & Joint Surgery - British Volume. Sep. 2007;89(9):1210-7.
97 Mattsson P, Alberts A, Dahlberg G, et al. Resorbable cement for the augmentation of internally-fixed unstable trochanteric fractures. A prospective, randomised multicentre study. Journal of Bone & Joint Surgery - British Volume. Sep. 2005;87(9):1203-9.
98 Pajarinen J, Lindahl J, Michelsson O, et al. Pertrochanteric femoral fractures treated with a dynamic hip screw or a proximal femoral nail. A randomised study comparing post-operative rehabilitation. Journal of Bone & Joint Surgery - British Volume. Jan. 2005;87(1):76-81.
99 Ahrengart L, Tornkvist H, Fornander P, et al. A randomized study of the compression hip screw and Gamma nail in 426 fractures. Clinical Orthopaedics & Related Research. Aug. 2002;(401):209-22. [pmid: 12151898].
100 Saudan M, Lubbeke A, Sadowski C, et al. Pertrochanteric fractures: is there an advantage to an intramedullary nail?: a randomized, prospective study of 206 patients comparing the dynamic hip screw and proximal femoral nail. Journal of Orthopaedic Trauma. Jul. 2002;16(6):386-93. [pmid: 12142826].
101 Brandt SE, Lefever S, Janzing HMJ, et al. Percutaneous compression plating (PCCP) versus the dynamic hip screw for pertrochanteric hip fractures: preliminary results. Injury. Jun. 2002;33(5):413-8. [pmid: 12095721].
102 Harrington P, Nihal A, Singhania AK, et al. Intramedullary hip screw versus sliding hip screw for unstable intertrochanteric femoral fractures in the elderly. Injury. Jan. 2002;33(1):23-8. [pmid: 11879828].
103 Kosygan KP, Mohan R, Newman RJ. The Gotfried percutaneous compression plate compared with the conventional classic hip screw for the fixation of intertrochanteric fractures of the hip.[see comment]. Journal of Bone & Joint Surgery - British Volume. Jan. 2002;84(1):19-22.
104 Janzing HMJ, Houben BJJ, Brandt SE, et al. The Gotfried PerCutaneous Compression Plate versus the Dynamic Hip Screw in the treatment of pertrochanteric hip fractures: minimal invasive treatment reduces operative time and postoperative pain. Journal of Trauma-Injury Infection & Critical Care. Feb. 2002;52(2):293-8.
105 Dujardin FH, Benez C, Polle G, et al. Prospective randomized comparison between a dynamic hip screw and a mini-invasive static nail in fractures of the trochanteric area: preliminary results. Journal of Orthopaedic Trauma. Aug. 2001;15(6):401-6. [pmid: 11514766].
106 Adams CI, Robinson CM, Court-Brown CM, et al. Prospective randomized controlled trial of an intramedullary nail versus dynamic screw and plate for intertrochanteric fractures of the femur.[see comment]. Journal of Orthopaedic Trauma. Aug. 2001;15(6):394-400. [pmid: 11514765].
107 Olsson O, Ceder L, Hauggaard A. Femoral shortening in intertrochanteric fractures. A comparison between the Medoff sliding plate and the compression hip screw. Journal of Bone & Joint Surgery - British Volume. May. 2001;83(4):572-8.
108 Lunsjo K, Ceder L, Thorngren KG, et al. Extramedullary fixation of 569 unstable intertrochanteric fractures: a randomized multicenter trial of the Medoff sliding plate versus three other screw-plate systems. Acta Orthopaedica Scandinavica. Apr. 2001;72(2):133-40. [pmid: 11372943].
109 Lunsjo K, Ceder L, Tidermark J, et al. Extramedullary fixation of 107 subtrochanteric fractures: a randomized multicenter trial of the Medoff sliding plate versus 3 other screw-plate systems. Acta Orthopaedica Scandinavica. Oct. 1999;70(5):459-66. [pmid: 10622478].
110 Park SR, Kang JS, Kim HS, et al. Treatment of intertrochanteric fracture with the Gamma AP locking nail or by a compression hip screw--a randomised prospective trial. International Orthopaedics. 1998;22(3):157-60. [pmid: 9728307].
111 Madsen JE, Naess L, Aune AK, et al. Dynamic hip screw with trochanteric stabilizing plate in the treatment of unstable proximal femoral fractures: a comparative study with the Gamma nail and compression hip screw. Journal of Orthopaedic Trauma. May. 1998;12(4):241-8. [pmid: 9619458].
112 Hardy DC, Descamps PY, Krallis P, et al. Use of an intramedullary hip-screw compared with a compression hip-screw with a plate for intertrochanteric femoral fractures. A prospective, randomized study of one hundred patients.[see comment]. Journal of Bone & Joint Surgery - American Volume. May. 1998;80(5):618-30.
113 Watson JT, Moed BR, Cramer KE, et al. Comparison of the compression hip screw with the Medoff sliding plate for intertrochanteric fractures. Clinical Orthopaedics & Related Research. Mar. 1998;(348):79-86. [pmid: 9553537].
114 Hoffman CW, Lynskey TG. Intertrochanteric fractures of the femur: a randomized prospective comparison of the Gamma nail and the Ambi hip screw. Australian & New Zealand Journal of Surgery. Mar. 1996;66(3):151-5. [pmid: 8639131].
115 Butt MS, Krikler SJ, Nafie S, et al. Comparison of dynamic hip screw and gamma nail: a prospective, randomized, controlled trial. Injury. Nov. 1995;26(9):615-8. [pmid: 8550169].
116 O'Brien PJ, Meek RN, Blachut PA, et al. Fixation of intertrochanteric hip fractures: gamma nail versus dynamic hip screw. A randomized, prospective study. Canadian Journal of Surgery. Dec. 1995;38(6):516-20.
117 Stappaerts KH, Deldycke J, Broos PL, et al. Treatment of unstable peritrochanteric fractures in elderly patients with a compression hip screw or with the Vandeputte (VDP) endoprosthesis: a prospective randomized study.[see comment]. Journal of Orthopaedic Trauma. 1995;9(4):292-7. [pmid: 7562150].
118 Goldhagen PR, O'Connor DR, Schwarze D, et al. A prospective comparative study of the compression hip screw and the gamma nail. Journal of Orthopaedic Trauma. Oct. 1994;8(5):367-72. [pmid: 7996318].
119 Aune AK, Ekeland A, Odegaard B, et al. Gamma nail vs compression screw for trochanteric femoral fractures. 15 reoperations in a prospective, randomized study of 378 patients. Acta Orthopaedica Scandinavica. Apr. 1994;65(2):127-30. [pmid: 8197841].
120 van Vugt AB, Oosterwijk WM, Goris RJ. Osteosynthesis versus endoprosthesis in the treatment of unstable intracapsular hip fractures in the elderly. A randomised clinical trial. Archives of Orthopaedic & Trauma Surgery. 1993;113(1):39-45. [pmid: 8117509].
121 Radford PJ, Needoff M, Webb JK. A prospective randomised comparison of the dynamic hip screw and the gamma locking nail. Journal of Bone & Joint Surgery - British Volume. Sep. 1993;75(5):789-93.
122 Leung KS, So WS, Shen WY, et al. Gamma nails and dynamic hip screws for peritrochanteric fractures. A randomised prospective study in elderly patients. Journal of Bone & Joint Surgery - British Volume. May. 1992;74(3):345-51.
123 Bridle SH, Patel AD, Bircher M, et al. Fixation of intertrochanteric fractures of the femur. A randomised prospective comparison of the gamma nail and the dynamic hip screw. Journal of Bone & Joint Surgery - British Volume. Mar. 1991;73(2):330-4.
124 Skinner P, Riley D, Ellery J, et al. Displaced subcapital fractures of the femur: a prospective randomized comparison of internal fixation, hemiarthroplasty and total hip replacement. Injury. Sep. 1989;20(5):291-3. [pmid: 2693355].
125 Madsen F, Linde F, Andersen E, et al. Fixation of displaced femoral neck fractures. A comparison between sliding screw plate and four cancellous bone screws. Acta Orthopaedica Scandinavica. Jun. 1987;58(3):212-6. [pmid: 3307282].
126 Linde F, Andersen E, Hvass I, et al. Avascular femoral head necrosis following fracture fixation. Injury. May. 1986;17(3):159-63. [pmid: 3818052].
127 El-Abed K, McGuinness A, Brunner J, et al. Comparison of outcomes following uncemented hemiarthroplasty and dynamic hip screw in the treatment of displaced subcapital hip fractures in patients aged greater than 70 years. Acta Orthopaedica Belgica. Feb. 2005;71(1):48-54. [pmid: 15792207].
128 Davison JN, Calder SJ, Anderson GH, et al. Treatment for displaced intracapsular fracture of the proximal femur. A prospective, randomised trial in patients aged 65 to 79 years.[see comment]. Journal of Bone & Joint Surgery - British Volume. Mar. 2001;83(2):206-12.
129 Ravikumar KJ, Marsh G. Internal fixation versus hemiarthroplasty versus total hip arthroplasty for displaced subcapital fractures of femur--13 year results of a prospective randomised study. Injury. Dec. 2000;31(10):793-7. [pmid: 11154750].
130 Benterud JG, Husby T, Nordsletten L, et al. Fixation of displaced femoral neck fractures with a sliding screw plate and a cancellous screw or two Olmed screws. A prospective, randomized study of 225 elderly patients with a 3-year follow-up. Annales Chirurgiae et Gynaecologiae. 1997;86(4):338-42. [pmid: 9474428].
131 Kuokkanen H, Korkala O, Antti-Poika I, et al. Three cancellous bone screws versus a screw-angle plate in the treatment of Garden I and II fractures of the femoral neck. Acta Orthopaedica Belgica. 1991;57(1):53-7. [pmid: 2038944].
132 Ekstrom W, Karlsson-Thur C, Larsson S, et al. Functional outcome in treatment of unstable trochanteric and subtrochanteric fractures with the proximal femoral nail and the Medoff sliding plate. Journal of Orthopaedic Trauma. Jan. 2007;21(1):18-25. [pmid: 17211264].
133 Buciuto R, Uhlin B, Hammerby S, et al. RAB-plate vs Richards CHS plate for unstable trochanteric hip fractures. A randomized study of 233 patients with 1-year follow-up.[see comment]. Acta Orthopaedica Scandinavica. Feb. 1998;69(1):25-8. [pmid: 9524512].
134 Efstathopoulos NE, Nikolaou VS, Lazarettos JT. Intramedullary fixation of intertrochanteric hip fractures: a comparison of two implant designs. International Orthopaedics. Feb. 2007;31(1):71-6. [pmid: 16736148].
135 Schipper IB, Steyerberg EW, Castelein RM, et al. Treatment of unstable trochanteric fractures. Randomised comparison of the gamma nail and the proximal femoral nail. Journal of Bone & Joint Surgery - British Volume. Jan. 2004;86(1):86-94.
136 Herrera A, Domingo LJ, Calvo A, et al. A comparative study of trochanteric fractures treated with the Gamma nail or the proximal femoral nail. International Orthopaedics. 2002;26(6):365-9. [pmid: 12466870].
137 Fritz T, Hiersemann K, Krieglstein C, et al. Prospective randomized comparison of gliding nail and gamma nail in the therapy of trochanteric fractures. Archives of Orthopaedic & Trauma Surgery. 1999;119(1–2):1-6. [pmid: 10076936].
138 Vidyadhara S, Rao SK. One and two femoral neck screws with intramedullary nails for unstable trochanteric fractures of femur in the elderly--randomised clinical trial. Injury. Jul. 2007;38(7):806-14. [pmid: 17049347].
139 Hardy DCR, Drossos K. Slotted intramedullary hip screw nails reduce proximal mechanical unloading. Clinical Orthopaedics & Related Research. Jan. 2003;(406):176-84. [pmid: 12579017].
140 Kim S-Y, Kim Y-G, Hwang J-K. Cementless calcar-replacement hemiarthroplasty compared with intramedullary fixation of unstable intertrochanteric fractures. A prospective, randomized study. Journal of Bone & Joint Surgery - American Volume. Oct. 2005;87(10):2186-92.
141 Jonsson B, Sernbo I, Carlsson A, et al. Social function after cervical hip fracture. A comparison of hook-pins and total hip replacement in 47 patients. Acta Orthopaedica Scandinavica. Oct. 1996;67(5):431-4. [pmid: 8948244].
142 Herngren B, Mork-Petersen F, Bauer M. Uppsala screws or Hansson pins for internal fixation of femoral neck fractures? A prospective study of 180 cases. Acta Orthopaedica Scandinavica. Feb. 1992;63(1):41-6. [pmid: 1738969].
143 Olerud C, Rehnberg L, Hellquist E. Internal fixation of femoral neck fractures. Two methods compared. Journal of Bone & Joint Surgery - British Volume. Jan. 1991;73(1):16-9.
144 Jacobsson B, Dalen N. Femoral head vitality after peroperative impaction of hip fractures. Acta Orthopaedica Scandinavica. Aug. 1985;56(4):312-3. [pmid: 4072647].
145 Lagerby M, Asplund S, Ringqvist I. Cannulated screws for fixation of femoral neck fractures. No difference between Uppsala screws and Richards screws in a randomized prospective study of 268 cases. Acta Orthopaedica Scandinavica. Aug. 1998;69(4):387-91. [pmid: 9798447].
146 Roden M, Schon M, Fredin H. Treatment of displaced femoral neck fractures: a randomized minimum 5-year follow-up study of screws and bipolar hemiprostheses in 100 patients. Acta Orthopaedica Scandinavica. Feb. 2003;74(1):42-4. [pmid: 12635791].
147 Parker MJ, Khan RJK, Crawford J, et al. Hemiarthroplasty versus internal fixation for displaced intracapsular hip fractures in the elderly. A randomised trial of 455 patients. Journal of Bone & Joint Surgery - British Volume. Nov. 2002;84(8):1150-5.
148 Parker MJ, Pryor GA. Internal fixation or arthroplasty for displaced cervical hip fractures in the elderly: a randomised controlled trial of 208 patients. Acta Orthopaedica Scandinavica. Oct. 2000;71(5):440-6. [pmid: 11186397].
149 van Dortmont LM, Douw CM, van Breukelen AM, et al. Cannulated screws versus hemiarthroplasty for displaced intracapsular femoral neck fractures in demented patients. Annales Chirurgiae et Gynaecologiae. 2000;89(2):132-7. [pmid: 10905680].
150 Mattsson P, Larsson S. Calcium phosphate cement for augmentation did not improve results after internal fixation of displaced femoral neck fractures: a randomized study of 118 patients. Acta Orthopaedica. Apr. 2006;77(2):251-6. [pmid: 16752286].
151 Johansson T, Bachrach-Lindstrom M, Aspenberg P, et al. The total costs of a displaced femoral neck fracture: comparison of internal fixation and total hip replacement. A randomised study of 146 hips. International Orthopaedics. Feb. 2006;30(1):1-6. [pmid: 16374651].
152 Blomfeldt R, Tornkvist H, Ponzer S, et al. Comparison of internal fixation with total hip replacement for displaced femoral neck fractures. Randomized, controlled trial performed at four years. Journal of Bone & Joint Surgery - American Volume. Aug. 2005;87(8):1680-8.
153 Mattsson P, Larsson S. Stability of internally fixed femoral neck fractures augmented with resorbable cement. A prospective randomized study using radiostereometry. Scandinavian Journal of Surgery: SJS. 2003;92(3):215-9. [pmid: 14582545].
154 Tidermark J. Quality of life and femoral neck fractures. Acta Orthopaedica Scandinavica. Apr. 2003;Supplementum 74(309):1-42. [pmid: 12811943].
155 Tidermark J, Ponzer S, Svensson O, et al. Internal fixation compared with total hip replacement for displaced femoral neck fractures in the elderly. A randomised, controlled trial.[see comment]. Journal of Bone & Joint Surgery - British Volume. Apr. 2003;85(3):380-8.
156 Johansson T, Risto O, Knutsson A, et al. Heterotopic ossification following internal fixation or arthroplasty for displaced femoral neck fractures: a prospective randomized study. International Orthopaedics. 2001;25(4):223-5. [pmid: 11561495].
157 Johansson T, Jacobsson SA, Ivarsson I, et al. Internal fixation versus total hip arthroplasty in the treatment of displaced femoral neck fractures: a prospective randomized study of 100 hips. Acta Orthopaedica Scandinavica. Dec. 2000;71(6):597-602. [pmid: 11145387].
158 Bachrach-Lindstrom M, Johansson T, Unosson M, et al. Nutritional status and functional capacity after femoral neck fractures: a prospective randomized one-year follow-up study. Aging-Clinical & Experimental Research. Oct. 2000;12(5):366-74.
159 Neander G, Adolphson P, von Sivers K, et al. Bone and muscle mass after femoral neck fracture. A controlled quantitative computed tomography study of osteosynthesis versus primary total hip arthroplasty. Archives of Orthopaedic & Trauma Surgery. 1997;116(8):470-4. [pmid: 9352040].
160 Puolakka TJ, Laine HJ, Tarvainen T, et al. Thompson hemiarthroplasty is superior to Ullevaal screws in treating displaced femoral neck fractures in patients over 75 years. A prospective randomized study with two-year follow-up. Annales Chirurgiae et Gynaecologiae. 2001;90(3):225-8. [pmid: 11695801].
161 Blomfeldt R, Tornkvist H, Ponzer S, et al. Internal fixation versus hemiarthroplasty for displaced fractures of the femoral neck in elderly patients with severe cognitive impairment.[see comment][erratum appears in J Bone Joint Surg Br. 2005 Aug;87(8):1166]. Journal of Bone & Joint Surgery - British Volume. Apr. 2005;87(4):523-9.
162 Emery RJ, Broughton NS, Desai K, et al. Bipolar hemiarthroplasty for subcapital fracture of the femoral neck. A prospective randomised trial of cemented Thompson and uncemented Moore stems. Journal of Bone & Joint Surgery - British Volume. Mar. 1991;73(2):322-4.
163 Baker RP, Squires B, Gargan MF, et al. Total hip arthroplasty and hemiarthroplasty in mobile, independent patients with a displaced intracapsular fracture of the femoral neck. A randomized, controlled trial.[see comment]. Journal of Bone & Joint Surgery - American Volume. Dec. 2006;88(12):2583-9.
164 Raia FJ, Chapman CB, Herrera MF, et al. Unipolar or bipolar hemiarthroplasty for femoral neck fractures in the elderly?. Clinical Orthopaedics & Related Research. Sep. 2003;(414):259-65. [pmid: 12966301].
165 Christie J, Burnett R, Potts HR, et al. Echocardiography of transatrial embolism during cemented and uncemented hemiarthroplasty of the hip. Journal of Bone & Joint Surgery - British Volume. May. 1994;76(3):409-12.
166 Blomfeldt R, Tornkvist H, Eriksson K, et al. A randomised controlled trial comparing bipolar hemiarthroplasty with total hip replacement for displaced intracapsular fractures of the femoral neck in elderly patients. Journal of Bone & Joint Surgery - British Volume. Feb. 2007;89(2):160-5.
167 Cornell CN, Levine D, O'Doherty J, et al. Unipolar versus bipolar hemiarthroplasty for the treatment of femoral neck fractures in the elderly.[see comment]. Clinical Orthopaedics & Related Research. Mar. 1998;(348):67-71. [pmid: 9553535].
168 Karagiannis A, Papakitsou E, Dretakis K, et al. Mortality rates of patients with a hip fracture in a southwestern district of Greece: ten-year follow-up with reference to the type of fracture. Calcified Tissue International. Feb. 2006;78(2):72-7. [pmid: 16467975].
169 Cornwall R, Gilbert MS, Koval KJ, et al. Functional outcomes and mortality vary among different types of hip fractures: a function of patient characteristics. Clinical Orthopaedics & Related Research. Aug. 2004;(425):64-71. [pmid: 15292789].
170 Heikkinen T, Willig R, Hanninen A, et al. Hip fractures in Finland--a comparison of patient characteristics and outcomes in six hospitals. Scandinavian Journal of Surgery: SJS. 2004;93(3):234-40. [pmid: 15544081].
171 Borgquist L, Nordell E, Lindelow G, et al. Outcome after hip fracture in different health care districts. Rehabilitation of 837 consecutive patients in primary care 1986–88. Scandinavian Journal of Primary Health Care. Dec. 1991;9(4):244-51. [pmid: 1792449].
172 Holt G, Macdonald D, Fraser M, et al. Outcome after surgery for fracture of the hip in patients aged over 95 years. Journal of Bone & Joint Surgery - British Volume. Aug. 2006;88(8):1060-4.
173 Penrod JD, Litke A, Hawkes WG, et al. The association of race, gender, and comorbidity with mortality and function after hip fracture. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. Aug. 2008;63(8):867-72.
174 Holt G, Smith R, Duncan K, et al. Gender differences in epidemiology and outcome after hip fracture: evidence from the Scottish Hip Fracture Audit. Journal of Bone & Joint Surgery - British Volume. Apr. 2008;90(4):480-3.
175 Aharonoff GB, Koval KJ, Skovron ML, et al. Hip fractures in the elderly: predictors of one year mortality. Journal of Orthopaedic Trauma. Apr. 1997;11(3):162-5. [pmid: 9181497].
176 Chariyalertsak S, Suriyawongpisal P, Thakkinstain A. Mortality after hip fractures in Thailand. International Orthopaedics. 2001;25(5):294-7. [pmid: 11794262].
177 Trombetti A, Herrmann F, Hoffmeyer P, et al. Survival and potential years of life lost after hip fracture in men and age-matched women. Osteoporosis International. Sep. 2002;13(9):731-7. [pmid: 12195537].
178 Alegre-Lopez J, Cordero-Guevara J, Alonso-Valdivielso JL, et al. Factors associated with mortality and functional disability after hip fracture: an inception cohort study. Osteoporosis International. Jul. 2005;16(7):729-36. [pmid: 15526089].
179 Pioli G, Barone A, Giusti A, et al. Predictors of mortality after hip fracture: results from 1-year follow- up. Aging-Clinical & Experimental Research. Oct. 2006;18(5):381-7. [pmid: 17167302].
180 Mossey JM, Mutran E, Knott K, et al. Determinants of recovery 12 months after hip fracture: the importance of psychosocial factors. American Journal of Public Health. Mar. 1989;79(3):279-86. [pmid: 2916712].
181 Penrod JD, Litke A, Hawkes WG, et al. Heterogeneity in hip fracture patients: age, functional status, and comorbidity. Journal of the American Geriatrics Society. Mar. 2007;55(3):407-13. [pmid: 17341244].
182 Eastwood EA, Magaziner J, Wang J, et al. Patients with hip fracture: subgroups and their outcomes. Journal of the American Geriatrics Society. Jul. 2002;50(7):1240-9. [pmid: 12133019].
183 Keating JF, Grant A, Masson M, et al. Displaced intracapsular hip fractures in fit, older people: a randomised comparison of reduction and fixation, bipolar hemiarthroplasty and total hip arthroplasty. Health Technology Assessment. Oct. 2005;9(41):iii-iv. ix. x. 1. 65. [pmid: 16202351].
184 Rogmark C, Carlsson A, Johnell O, et al. A prospective randomised trial of internal fixation versus arthroplasty for displaced fractures of the neck of the femur. Functional outcome for 450 patients at two years.[see comment]. Journal of Bone & Joint Surgery - British Volume. Mar. 2002;84(2):183-8.
185 Alho A, Austdal S, Benterud JG, et al. Biases in a randomized comparison of three types of screw fixation in displaced femoral neck fractures. Acta Orthopaedica Scandinavica. Oct. 1998;69(5):463-8. [pmid: 9855225].
186 Fox KM, Magaziner J, Hebel JR, et al. Intertrochanteric versus femoral neck hip fractures: differential characteristics, treatment, and sequelae. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. Dec. 1999;54(12):M635-40.
187 Siu AL, Penrod JD, Boockvar KS, et al. Early ambulation after hip fracture: effects on function and mortality. Archives of Internal Medicine. Apr. 10. 2006;166(7):766-71. [pmid: 16606814].
188 Paksima N, Koval KJ, Aharanoff G, et al. Predictors of mortality after hip fracture: a 10-year prospective study. Bulletin of the NYU Hospital for Joint Diseases. 2008;66(2):111-7. [pmid: 18537780].
189 Cree M, Soskolne CL, Belseck E, et al. Mortality and institutionalization following hip fracture. Journal of the American Geriatrics Society. Mar. 2000;48(3):283-8. [pmid: 10733054].
190 Fox KM, Hawkes WG, Hebel JR, et al. Mobility after hip fracture predicts health outcomes. Journal of the American Geriatrics Society. Feb. 1998;46(2):169-73. [pmid: 9475444].
191 Schlag G, Gaudernak T, Pelinka H, et al. Thromboembolic prophylaxis in hip fracture. Acta Orthopaedica Scandinavica. Aug. 1986;57(4):340-3. [pmid: 3788500].
192 Keating JF, Grant A, Masson M, et al. Randomized comparison of reduction and fixation, bipolar hemiarthroplasty, and total hip arthroplasty. Treatment of displaced intracapsular hip fractures in healthy older patients. Journal of Bone & Joint Surgery - American Volume. Feb. 2006;88(2):249-60.
193 Dorr LD, Glousman R, Hoy AL, et al. Treatment of femoral neck fractures with total hip replacement versus cemented and noncemented hemiarthroplasty. Journal of Arthroplasty. 1986;1(1):21-8. [pmid: 3559574].
194 Livesley PJ, Srivastiva VM, Needoff M, et al. Use of a hydroxyapatite-coated hemiarthroplasty in the management of subcapital fractures of the femur. Injury. Apr. 1993;24(4):236-40. [pmid: 8392032].
195 Bajammal SS, Zlowodzki M, Lelwica A, et al. The use of calcium phosphate bone cement in fracture treatment. A meta-analysis of randomized trials. Journal of Bone & Joint Surgery - American Volume. Jun. 2008;90(6):1186-96.
196 Parker MJ, Blundell C. Choice of implant for internal fixation of femoral neck fractures. Meta-analysis of 25 randomised trials including 4,925 patients. Acta Orthopaedica Scandinavica. Apr. 1998;69(2):138-43. [pmid: 9602770].
197 Parker MJ, Stockton G. Internal fixation implants for intracapsular proximal femoral fractures in adults. Cochrane Database of Systematic Reviews. 2001;(4):CD001467. [pmid: 11687113].
198 Reindl R, Steffen T, Cohen L, et al. Elective lumbar spinal decompression in the elderly: is it a high-risk operation?. Canadian Journal of Surgery. Feb. 2003;46(1):43-6.
199 Forte ML, Virnig BA, Feldman R, et al. Surgeon and hospital factors associated with the use of differentially-reimbursed hip fracture procedures. AcadamyHealth. Washington, DC. 2008.
200 Fisher ES, Baron JA, Malenka DJ, et al. Hip fracture incidence and mortality in New England. Epidemiology. Mar. 1991;2(2):116-22. [pmid: 1932308].
201 Oremus M, Santaguida P, Walker K, et al. Methodological issues in evaluation of innovative training approaches to stroke rehabilitation. Prepared by McMaster University Evidence-based Practice Center for the Agency for Healthcare Research and Quality under Contract No. HHSA-290-2007-10060-I. Available at: http://www.cms.hhs.gov/determinationprocess/downloads/id59TA.pdf. Accessed February 12, 2009.
202 Kane RL, Saleh KJ, Wilt TJ, et al. Total Knee Replacement. Rockville, MD. Prepared by the Minnesota Evidence-based Practice Center for the Agency for Healthcare. Research and Quality under contract No. 290-02-0009; Evidence Report/Technology Assessment No. 86, AHRQ Publication No. 04-E006-2. December. 2003.
203 Fung W, Jonsson A, Buhren V, et al. Classifying intertrochanteric fractures of the proximal femur: does experience matter?. Medical Principles & Practice. 2007;16(3):198-202. [pmid: 17409754].