# Executive Summary

## Introduction

Hip fractures rank in the top ten of all impairments worldwide in terms of loss in disability-adjusted years for people 50+ years old.1 The absolute number of hip fracture hospitalizations in the United States is currently about 310,000,^2^ and this number is expected to continue to rise due to increased life spans and an aging baby boom generation. Ninety percent of hip fractures result from a simple fall;3 therefore, efforts to prevent hip fractures are unlikely to have a substantial impact on hip fracture incidence.4–7

The consequences for hip fractures in elderly individuals are significant in terms of lives lost and the associated negative impacts on hip fracture patients’ functioning and quality of life.8 One year mortality for patients after a hip fracture is approximately 20 percent, with men, patients older than 75 years, and nursing home patients at higher risk.4,9–11 However, it is not clear how much of that mortality is due to the fracture and its sequelae and how much to the underlying frailty that may predispose a person to a fracture.12 Morbidity associated with hip fractures may include serious complications, such as deep vein thrombosis and postoperative infection, muscular deconditioning, pain, and loss of mobility.4 Among patients who were living independently prior to a hip fracture, only about half are able to walk unaided after fracture,13,14 and about one-fifth require long-term placement in a care facility.15,16

Hip fractures are generally classified into three major types, depending on the specific location of the fracture: femoral neck, intertrochanteric, and subtrochanteric fractures. The term pertrochanteric hip fracture may also be used in hip fracture literature and refers to a more inclusive set of extracapsular fractures, including intertrochanteric, subtrochanteric, and mixed fracture patterns.6

Femoral neck fractures occur in the narrowed section of the upper femur between the rounded femoral head and bony projections called trochanters. Femoral neck fractures are grouped into nondisplaced and displaced fractures by the alignment of the fractured segments in relation to the original anatomic position of the femur.

Intertrochanteric hip fractures occur in the area between the greater and lesser trochanters. The trochanters are bony projections where major hip muscles attach. Intertrochanteric fractures may be further grouped into stable and unstable fractures, depending on the location, number, and size of the fractured bony segments.

Subtrochanteric fractures occur at or below the level of the lesser trochanter in the upper portion of the femur. Isolated subtrochanteric fractures occur in the area between the upper border of the lesser trochanter to 5 cm below it, toward the knee. Subtrochanteric fractures may include only a short, linear section of the proximal femur or may be part of a larger fracture pattern that involves both the intertrochanteric and subtrochanteric sections of the femur. Orthopaedic surgeons differ on their definition of subtrochanteric fractures, and may also consider fractures that extend further toward the knee to be subtrochanteric.

Michelson et al.,17 found that the distribution of the types of hip fractures within the U.S. population is 49 percent intertrochanteric, 37 percent femoral neck, and 14 percent subtrochanteric, and these estimates are relatively consistent across authors.11,18,19 The proportions are reliant on the classification system used and the preferences of surgeons in labeling fracture patterns.

The vast majority of hip fracture patients are treated with surgical repair. The short-term goal of surgical treatment is to stabilize the hip fracture enough to withstand early mobilization and weight bearing, which prevents complications due to prolonged bed rest and aids in fracture healing. The type of surgery is generally based on the fracture pattern and patient characteristics. Pertrochanteric fractures are generally managed with internal fixation, most often plate/screw devices or intramedullary nails. Femoral neck fractures are treated with either internal fixation or arthroplasty. Hemiarthroplasty replaces the femoral head segment of the upper femur with an artificial implant. The patient’s own acetabulum is not replaced. Total hip arthroplasty is the prosthetic replacement of the entire hip joint, both the femoral head and the acetabulum within the pelvis.

The goal of treatment for hip fractures is to return patients to their pre-fracture level of function.6,20,21 There is a growing body of literature on treatment options and their effects on intermediary and patient post-surgical treatment outcomes, including several systematic reviews; however, no comprehensive organization of the evidence across all types of geriatric hip fractures currently exists. The aim of the present project was to conduct a systematic review and synthesize the evidence of the effects of surgical treatments of fractures of the hip on patient post-treatment outcomes, which to date have received only modest attention, but which are central to the patient’s experience.

## Key Questions and Conceptual Model

This review was asked to address the following key questions:

- Key Question 1 – What is the relationship between patient variables, the type of fracture and patient post-treatment outcomes, such as pain and functioning?
- Key Question 2 – What is the relationship between the type of fracture and patient post‐treatment outcomes?
- Key Question 3 – What is the relationship between implant variables and patient post‐treatment outcomes?
- Key Question 4 – What is the relationship between the type of intervention and patient post-treatment outcomes?

Key question 1 examines the larger question of how patient characteristics, including fracture type, relate to patient outcomes, while key question 2 focuses specifically on the relationship between fracture type and outcome, holding patient characteristics steady. Key questions 3 and 4 are differentiated by the level of analysis of device type, either at the level of specific device or whole classes of devices.

Fracture types and treatment choices are strongly correlated, so the ability to tease apart the separate effects of fracture type and surgical treatment on patient outcomes requires a comprehensive model that would account for the major variables that may impact patient post‐treatment outcomes. These variables would include patient characteristics, factors that contribute to the surgical treatments, such as the hospital setting, surgeon factors, and factors related to operative procedures, and post-acute rehabilitation processes.

The review is focused on the patient population most likely to experience hip fractures due to low energy trauma, and the final patient outcomes of mortality, functional status, and quality of life. Patients younger than age 50, and fractures due to high energy trauma, are outside the scope of this review. External fixators, or devices or surgical methods that are no longer in common use within the United States, are also outside the scope of this review.

## Methods

The search strategy included a list of terms intended to identify all research publications associated with intertrochanteric/subtrochanteric and subcapital hip fractures. Searches for trials were further limited by terms to identify types of surgical implant interventions. Electronic searches of MEDLINE^®^, Cochrane databases, Scirus, and ClinicalTrials.gov were conducted. We also manually searched reference lists from relevant systematic reviews.

The patient population inclusion criteria were age of 50 or older with a nonpathologic fracture that resulted from low energy trauma, and index fractures. Implantable devices must have been available for use in the United States or be similar enough to U.S. devices that the results were meaningful. Excluded devices were either experimental or no longer in clinical use in North America. All retained devices have characteristics that are generally the same as implants that remain in use in North America. All devices were reviewed by orthopaedic clinician authors for inclusion/exclusion status. Decisions were based on clinical experience and/or examining specifications and images of the device in question. Opinions from Technical Expert Panel (TEP) members were sought and TEP members vetted the final list. Because of overlapping clinical terminology within the studies, all types of femoral neck or intracapsular fractures were included.

Articles for key questions 1 and 2 were primarily observational cohort studies limited to those with prospectively collected data and some form of multivariate analysis. Included studies were required to specifically involve research questions aimed at understanding the relationship between patient characteristics, fracture type, and patient outcomes. We retained cohort studies that simultaneously evaluated patients that had either a femoral neck or pertrochanteric fracture, and the fracture type was entered as an independent variable in the multivariate analysis. Patient populations needed to be at least 200 to allow for sizeable enough numbers in each analysis group. Only full journal articles for randomized controlled trials (RCTs) were included because we were focused on a comprehensive approach to patient outcomes, utilizing all factors that might impact patient outcomes. Articles were not excluded based on country of research origin. Key questions 3 and 4 were limited to only RCTs.

Two independent reviewers screened and abstracted all articles using standardized forms. At least two researchers quality checked each evidence table. Differences were resolved through consensus.

The literature was mapped using decision-tree mapping techniques, and the literature was grouped into up to four levels of comparisons. The maps are not comprehensive of all possible decision sets regarding implantable devices for hip fractures as the literature itself does not include RCTs for all decision sets.

When measured patient outcomes were consistent across studies (e.g. mortality), quantitative analysis was performed. A qualitative approach was employed for all other patient outcomes. Results of the quantitative and qualitative analyses are compared to relevant published systematic reviews for consistency of findings. (See Appendix A for details of systematic reviews.)

Only one article focused exclusively on subtrochanteric fractures; therefore, we relied on the intertrochanteric literature where it included subtrochanteric fractures or intertrochanteric fractures with subtrochanteric extensions. As the classification systems do not by themselves provide adequate assurance of identification of subtrochanteric fracture, we relied on subtrochanteric involvement as defined by the study investigators.

We employed a threshold approach to determining which articles to retain. This threshold was set lower than may otherwise normally be applied for a systematic review. Study quality was assessed based on an item checklist,22 with slight modifications. Since allocation concealment is not fully possible for surgical procedures, we placed a heavier weight on the randomization process and evidence of changes which might impact selection bias, whether the article provided sufficient information on the patient sample, and how carefully the patient sample was defined. Therefore, articles which excluded baseline information on the patient sample by group, or articles that did not provide exclusion criteria, were given lower quality ratings. Likewise, lack of information regarding attrition due to mortality and losses to followup was also weighted more heavily. With such large expected loss to mortality within the first year after a hip fracture, the total loss to followup can be substantial. Articles were retained for the review if they exceeded a minimum quality threshold that allowed for meaningful interpretations of patient samples. The body of evidence was rated according to the GRADE methods.23 Although the extent of heterogeneity among studies and lack of patient outcomes precluded formal meta-analysis and pooling, we sought to explore the patterns across study groupings.

## Results

The search string for RCTs generated 625 unique references, of which 81 articles were retained representing 76 unique studies; 35 trials for femoral neck fractures, 40 trials for intertrochanteric fractures, and one trial for subtrochanteric fractures. The literature is overwhelmingly international, with only five published trials originating in the United States. Nine observational studies were retained for key questions 1 and 2.

### RCT Study Outcomes

For both femoral neck and pertrochanteric fractures, most head to head RCT comparisons of hip fracture treatments compared classes of fracture repair devices in the absence of supporting RCT literature to show equivalency of implants within classes. For example, a number of articles examined some form of internal fixation versus some form of arthroplasty for femoral neck fractures, but little RCT literature helped determine which forms of internal fixation yielded equivalent outcomes.

With the exception of mortality, there are few instances where similar patient outcomes were evaluated for similar patient populations undergoing the same device comparison, mainly due to inconsistent use of outcomes measures across studies.

### Key Question 1

In the observational literature, very little research specifically addressed the link between patient characteristics and outcome variables by fracture type. Increasing age, comorbidity, and lower prefracture functioning, were predictive of short-term (4 to 6 month) mortality and reduced or delayed recovery of functioning as measured by ability to live independently, independence in activities of daily living (ADL)/independent activities of daily living (IADL), and mobility. Other identified predictors of recovery included lower American Society of Anesthesiologists (ASA) score, prefracture community residence, and femoral neck fracture. Dementia was also predictive if poor functioning and mortality were combined into an adverse outcome measure. Overall, the same pattern of predictors is found for functioning at 1 year. These results were consistent with observational research that controlled for fracture type as part of case mix, and those studies which dropped fracture type from the final analysis because of nonsignificance at the univariate level.

The observational literature set did not consistently adjust for fracture patterns or use treatment factors, such as hospital or perioperative factors or surgical devices, as model components. It is uncertain whether the reported results would differ, particularly with regard to functional outcomes, had the observational literature included such factors. Currently, the evidence suggests it is reasonable to treat age, prefracture functioning, comorbidities, and cognitive impairment as predictors of hip fracture treatment mortality and functional outcomes, but other predictors may yet be found to be important. The lack of comprehensive data collection within either the observational or RCT literature prevents a definitive answer about the relationship between patient characteristics, fracture types, and patient outcomes.

### Key Question 2

The observational literature provides a small amount of evidence that, holding all other factors constant, type of fracture does not independently predict long-term post-treatment patient outcomes. There is limited evidence that intertrochanteric fracture patients experience a delayed recovery period in the short term. However, the literature does not reliably differentiate between stable and unstable intertrochanteric fractures. Until the concern with regard to the reliability of classifying unstable intertrochanteric fractures is addressed, a definitive answer regarding the role of fracture types in post-surgical outcomes cannot be provided.

The RCT literature does not allow for an analysis of the impact of fracture type on post‐treatment outcomes. In order to isolate the impact of fracture type, the analysis would need to hold constant other factors that might affect patient outcomes, and the literature is lacking in such covariates, such as patient characteristics, surgeon experience, or rehabilitation factors.. Although fracture stability and displacement within each of the main types of fractures can reasonably be expected to impact outcomes, the current RCT literature also does not allow for subtype analysis by fracture pattern, particularly for intertrochanteric hip fractures. While there is consistent classification of femoral neck fractures into displaced or nondisplaced subtypes across studies, there is great inconsistency in the classification of intertrochanteric fractures into stable and unstable subtypes.

### Key Question 3

In addition to the hospital setting factors discussed in key questions 1 and 2, surgeon and perioperative factors also contribute to the overall outcomes of a device-related surgical procedure and should be incorporated into analyses in order to isolate the effects of a device-specific procedure from the setting within which it was used. Unfortunately, few studies reported surgeon factors such as the surgeon’s general level of training and experience, the surgeon’s experience with the specific devices being tested, the degree of orthopaedic resident participation in surgical procedures, or the quality of the surgical techniques. Only two used surgeon factors in analyses relative to outcomes.

Of the two articles that examined surgeon experience, one found that good positioning of the device was predictive of 1 year outcomes, and there was a trend for better implant positioning with greater surgeon experience.24 The other study did not examine post-treatment outcomes, but found that experienced surgeons took less time, had better results for fracture reduction and implant positioning, and their patients experienced fewer complications than among inexperienced surgeons.25

Perioperative factors are frequently reported in the literature as intermediate outcomes, but no study used the perioperative factors further in analyses of patient outcomes.

Within the limitations of the literature using an incomplete set of covariates, overall, no major differences were found in mortality or other patient outcomes between different devices for either femoral neck or intertrochanteric fractures. Thus, there is insufficient evidence to support the use of one device over another within a class of devices for either femoral neck fractures or intertrochanteric fractures with regard to patient outcomes.

### Key Question 4

Similar to key question 3, within the limitations of the literature using an incomplete set of covariates, overall, no differences were found in mortality between different classes of devices. That is, there is insufficient evidence to support the use of plates/screws versus intramedullary nail devices for intertrochanteric hip fractures with regard to mortality. Likewise, there is insufficient evidence to support the use of different forms of arthroplasty, or arthroplasty versus internal fixation for femoral neck fractures.

For pain and functional outcomes for femoral neck fractures, on the surface it would appear that total hip arthroplasty (THA) tends to have improved outcomes over internal fixation, and authors of systematic reviews have suggested the evidence is strong enough to recommend THA for cognitively intact, independent elderly hip fracture patients.26,27 However, one systematic review found no difference in pain or functioning between patients who received internal fixation and patients who received arthroplasty.28 There also still remains the question of whether these positive findings for THA would continue to hold if the analysis included all the variables relevant to understanding patient outcomes.

The paucity of significant findings for pain and functional outcomes for intertrochanteric hip fractures suggests that neither plate/screw implants nor intramedullary nails can be claimed to produce superior patient outcomes. A few studies reported intramedullary nails were associated with higher pain but earlier improvements in weight bearing and mobility. However, these improvements were short lived, returning to nonsignificance within a few months to 1 year postoperatively. Further, there is also some disagreement within the systematic review literature, which tends to focus on intermediate outcomes such as complication rates. The Cochrane reviews have supported plate/screw devices as superior to intramedullary nails for both stable and unstable intertrochanteric hipfractures,29,30 while there is some evidence that plate/screw devices have higher complication rates when used for certain unstable AO/OTA 31-A3 fracture subtypes.31 The issue of implant superiority for intertrochanteric hip fractures may not be fully resolved until there is reliable agreement with regard to the classification of stable and unstable intertrochanteric fractures across orthopaedic studies. Kaplan et al.32 also suggest there is insufficient evidence to support specific internal fixation device recommendations for intertrochanteric hip fractures at this time.

The following table summarizes the research findings.

Summary of Evidence

Patient Group | Strength of Evidence | Findings and Guidance
Femoral Neck – Displaced, generally independent or semi- independent, mobile elderly patients | Low 10 studies, N=1,968 Comparisons of IF | - No differences in patient outcomes between IF devices.; - No recommendation for type of IF based on patient outcomes.; - Surgeon experience and precision of implant placement may mediate intermediate outcomes.
Femoral Neck – Displaced, generally independent or semi- independent, mobile elderly patients | Low 9 studies, N=1,374 IF vs. hemi | - No long-term differences in patient outcomes between IF and hemiarthroplasty. Possibly shortened recovery period, 4 month outcomes, for hemiarthroplasty.; - No recommendation for device based on patient outcomes.
Femoral Neck – Displaced, generally independent or semi- independent, mobile elderly patients | Low 5 IF studies, N=526 IF vs. THA 3 hemi studies, N=332 Hemi vs. THA | - THA had better long-term improvements in pain and mobility than either IF or hemiarthroplasty.; - THA suggested based on patient outcomes for healthy elderly individuals most likely to gain from long-term functional improvements.; - Hemiarthroplasty reserved for patients with inadequate reduction and unlikely to see long-term functional benefits from surgical treatment.
Femoral Neck – Displaced, age 70+ years with cognitive impairment | Low 2 studies, N=120 IF vs. hemi | - No differences in patient outcomes between IF and hemiarthroplasty.; - Hemiarthroplasty reserved for patients with inadequate reduction.
Intertrochanteric – Unstable, all classifications, generally independent or semi-independent, mobile elderly patients | Low 32 studies, N=5,979 Comparisons of IF | - No differences in patient outcomes between IF devices.; - No recommendation for device based on patient outcomes.; - Surgeon experience and precision of implant placement may mediate intermediate outcomes.
Intertrochanteric – Unstable, AO/OTA 31-A2, 70+ years of age | Low 2 studies, N=148 IF vs. arthroplasty | - No differences in patient outcomes between IF and arthroplasty.; - Arthroplasty should be reserved for patients with degenerative arthritis, severe comminution, or highly osteoporitic bone.
Subtrochanteric – all classifications | Moderate 3 studies, N=148 Plate/Screw vs. IM | - No difference in patient outcomes between IF devices.; - No recommendation for device based on patient outcomes.
Reverse Oblique/Transverse – AO/OTA 31-A3 | Moderate 1 study, N=39 Plate/Screw vs. IM | - No difference in patient outcomes between IF devices.; - No recommendation for device based on patient outcomes.

IF = internal fixation; IM = intramedullary device; THA = total hip arthroplasty

## Discussion

The surgical treatment of hip fractures improves patients’ lives. In general, pain is reduced and function is restored after surgical treatment. About 75 percent of community dwelling elderly patients regain their prefracture independence by 1 year.33 However, outcomes differ by the pre-fracture status of the patient. Older age, lower prefracture functioning, and cognitive impairment are consistently associated with higher mortality and worse functional outcomes for hip fracture patients. Fracture type does not appear to be independently related to long-term patient outcomes, although limited evidence suggests that intertrochanteric hip fracture patients may experience initial and short-lived delays in recovery relative to femoral neck fracture patients. It is unclear whether these results would continue to hold if the analyses included the full complement of relevant and important covariates.

The summary table above summarizes the surgical treatment guidance based on patient-focused outcomes that can be drawn from the evidence at this time. Overall, mortality does not appear to differ by class of device or by devices within a class. Nor, on the whole, do pain, functioning, and quality of life vary by device. Very limited results suggest that femoral neck fracture patients with THA have improved patient outcomes over internal fixation.

A strong case cannot be made for specific surgical treatments at this time for several reasons. Patient outcomes associated with different techniques produce only modest differences, if any. In addition, the literature does not include full complements of potential covariates that are necessary to draw clinically-relevant conclusions. Moreover, the overall strength of the evidence is generally low. Finally, the literature comparing devices within a class is scant compared with device class comparisons themselves, which provides a weak foundation for suggesting any device class guidelines for the treatment of particular hip fracture patient populations.

Since surgical choices are not clearly differentiated by patient-focused outcomes in the available literature, guidelines for surgical repair of hip fractures will need to rely on intermediate outcomes and expert opinion for the present time. The failure of the literature to provide guidance should not be viewed as an insurmountable problem, but rather as opportunities for research improvements.

The temporal nature of the recovery from hip fracture also bears more attention. The gain for patients seems to lie in the immediate post-treatment time spent in a better functional state. Among the two-thirds of patients who, on average, survive the first year after hip fracture, functional gains seemed to hit a maximum at 1 year.34 Clinical trajectories converge by this point, or even earlier. Patients who were followed longer than 1 year generally showed functional declines. The policy implications thus involve putting a value on what can be thought of as the area under the curve. What is the value of an improved short-term recovery if the benefits for one device relative to another are short lived? This question takes on greater importance as the population ages and the fracture risks increase. At the same time, there are growing numbers of young elderly patients still working, for whom a shorter recovery period may have a direct impact on their income potential.35

Clinical trial quality within the past several years appears to be improving. Both the technical conduct of orthopaedic studies is improving and the outcomes perspective has been broadening to include patient input. We note both improvements in study conduct and improvements in the clarity of reporting, particularly in patient tracking and reporting post-discharge (better CONSORT compliance). This new initiative to improve outcomes reporting is likely to result in an increased ability to link fracture type, pattern, and implant to outcomes if well-designed, sufficiently powered trials with adequate followup and consistently used outcome measures, are conducted. Yet, based on our review of the literature, the broader hip fracture outcomes questions of interest cannot be fully answered with the existing literature.

Two main factors limit our ability to definitively answer the key questions posed in this study using the existing literature. The first factor is the limited perspective of discipline-specific investigations, which tend to use incomplete sets of important independent variables in study designs and models. The second factor is the generally low quality of hip fracture outcome studies, where specific populations are poorly defined and separated for comparative studies, and inconsistent outcome variables impede aggregating, or even comparing, results.

While the clinical study quality has improved within the last several years, the literature that was available for this review reflects a problem common to studies of musculoskeletal functional outcomes, a lack of consistent outcomes measurement. Other problems that substantially limit the strength of study conclusions are high or unreported patient attrition, inadequate power, and inadequate or unreported randomization schemes.

## Future Research Recommendations

A number of recommendations can be made to improve future research so that it might contribute to improved surgical guidelines.

- Encourage collaboration between the research communities rooted in different research disciplines and methodologies. Bringing together the surgeon’s perspective with regard to the importance of fracture types and patterns and device/surgery specifics and the epidemiologist’s understanding of the importance of patient factors on functional outcomes would enhance our understanding of hip fracture patients and help match best treatments to the patient populations most likely to benefit from them. The Journal of Bone and Joint Surgery published a series of articles addressing research design and potential contributions that well designed observational studies can provide to orthopaedic research.36–43
- Continue focusing on rigorous study design, sufficiently powered RCTs that follow CONSORT recommendations, and relevant functional outcomes. Multicenter, well-designed RCTs are necessary to evaluate results among patients with uncommon fracture patterns. Firm inclusion and exclusion criteria should be specified before embarking on RCTs and be strictly followed throughout enrollment to minimize post-randomization exclusions.
- Establish consensus on consistent definitions of stable and unstable intertrochanteric hip fractures within the most commonly used classification system(s). The use of obsolete classification systems should be avoided. At a minimum, the frequency of each fracture subtype among all patients should be included in all manuscripts and analyzed in relation to outcomes. This would not preclude authors from recommending refinement or switching to other classifications systems. But if those recommendations are made in addition to, and perhaps compared with, a classification standard, the ability to leverage the information across research studies would be greatly enhanced.
- Develop more inclusive conceptual models and use these as the basis for analyses. Surgical repair of hip fractures is a necessary critical step in restoring function to patients, but viewed in isolation it is insufficient to relate intervention to outcomes in the context of other critical factors. In order to isolate the effects of surgical treatments, research will need to incorporate measurements of all the major contributors to patient outcomes in order to control for them. Only a small portion of the published research for hip fracture surgical treatments collected such data, and even less incorporated the data into their analysis. Other patient characteristics important to understanding final outcomes may still need to be delineated. For example, fear of falling at 6 weeks post-surgery was a significant predictor of patient outcomes for hip fracture patients, in addition to cognitive impairment and depression.44 Patient outcomes may be affected by the inference the patient draws from the pain and the larger experience.
- Enhance reporting of surgeon variables. Define and quantify the quality of surgical techniques. As a few studies have begun to do, surgeons can quantify the quality of the fracture reduction postoperatively.45–47 Surgeons can also assess the technical quality of their implant placement immediately postoperatively.45,46,48,49 It would also be appropriate to identify and report surgeons’ level of experience with devices and procedures used for an RCT and, if possible, use this information in the analysis. The degree to which orthopaedic residents performed critical portions of surgical procedures should be identified.
- Consistently use validated quality of life and outcome assessment tools to improve comparability of outcomes across studies. A number of well-developed scales are available.50 Investigators need to resist the urge to tweak outcome measures; measures idiosyncratic to their own study should be accompanied by validated measures that allow for validation and ensure their study results will be amenable to pooling.
- Consider funding data pools wherever possible. This is particularly important for assessing infrequent events such as low frequency fracture patterns, specific complications, or patients who represent a small proportion of the overall patient base. The observational literature has taken the lead to date on pooling data across studies. For example, enough research exists to demonstrate gender differences in hip fracture risk factors and outcomes.11,51,52 Yet the research examined in this review found women to represent approximately 80 percent of the patient population across the studies. Within single studies this often does not provide sufficient power for subgroup analysis. Yet men that sustain a hip fracture are often sicker, at higher mortality risk than women, and differentially develop complications and respond to treatment.51
- Include and report on patients with cognitive impairments and dementia, with particular emphasis on patients admitted from nursing homes or other institutional residences. The issue of best treatments for the very frail elderly patients will continue to grow as the general population ages.