# Acknowledgments

We would like to thank Nancy Russell, Rebecca Schultz, and Karen Rashke for their help with editing and formatting this report, and especially Marilyn Eells for her editing, formatting, organizational skills, and her professionalism. We also thank all the individuals at AHRQ, the Scientific Resource Center, and the peer reviewers for their comments and suggestions.