# Discussion

## General Discussion

Overall, surgical treatment of hip fractures improves patients’ lives. In general, pain is reduced and functionality is restored after surgical treatment. About 75 percent of community dwelling elderly patients regain their prefracture independence by 1 year.33 However, outcomes differ with the underlying status of the patient. Older age, lower prefracture functioning, and cognitive impairment are consistently associated with higher mortality and worse functional outcomes for hip fracture patients. Fracture type does not appear to be independently related to long-term patient outcomes, although limited evidence suggests that intertrochanteric hip fracture patients may experience initial and short lived delays in recovery relative to femoral neck fracture patients. It is unclear whether these results would continue to hold if the analyses included the full complement of relevant covariates. Patient characteristics should matter to surgeons when choosing surgical treatments.

Table 9 summarizes the surgical treatment guidance based on patient focused outcomes that can be drawn from the evidence at this time. Overall, mortality does not appear to differ by class of device or by devices within a class. Nor, on the whole, do pain, functioning, and quality of life. Very limited results suggest that femoral neck fracture patients with THA have improved patient outcomes over internal fixation.

Table 9 Summary of evidence

Patient Group | Strength of Evidence | Findings and Guidance
Femoral Neck – Displaced, generally independent or semi- independent, mobile elderly patients | Low 10 studies, N=1,968 Comparisons of IF | - No differences in patient outcomes between IF devices.; - No recommendation for type of IF based on patient outcomes.; - Surgeon experience and precision of implant placement may mediate intermediate outcomes.
Femoral Neck – Displaced, generally independent or semi- independent, mobile elderly patients | Low 9 studies, N=1,374 IF vs. hemi | - No long-term differences in patient outcomes between IF and hemiarthroplasty. Possibly shortened recovery period, 4 month outcomes, for hemiarthroplasty.; - No recommendation for device based on patient outcomes.
Femoral Neck – Displaced, generally independent or semi- independent, mobile elderly patients | Low 5 IF studies, N=526 IF vs. THA 3 hemi studies, N=332 Hemi vs. THA | - THA had better long-term improvements in pain and mobility than either IF or hemiarthroplasty.; - THA suggested based on patient outcomes for healthy elderly individuals most likely to gain from long-term functional improvements.; - Hemiarthroplasty reserved for patients with inadequate reduction and unlikely to see long- term functional benefits from surgical treatment.
Femoral Neck – Displaced, age 70+ years with cognitive impairment | Low 2 studies, N=120 IF vs. hemi | - No differences in patient outcomes between IF and hemiarthroplasty.; - Hemiarthroplasty reserved for patients with inadequate reduction.
Intertrochanteric – Unstable, all classifications, generally independent or semi-independent, mobile elderly patients | Low 32 studies, N=5,979 Comparisons of IF | - No differences in patient outcomes between IF devices.; - No recommendation for device based on patient outcomes.; - Surgeon experience and precision of implant placement may mediate intermediate outcomes.
Intertrochanteric – Unstable, AO/OTA 31-A2, 70+ years of age | Low 2 studies, N=148 IF vs. arthroplasty | - No differences in patient outcomes between IF and arthroplasty.; - Arthroplasty should be reserved for patients with degenerative arthritis, severe comminution, or highly osteoporitic bone.
Subtrochanteric – all classifications | Moderate 3 studies, N=148 Plate/Screw vs. IM | - No difference in patient outcomes between IF devices.; - No recommendation for device based on patient outcomes.
Reverse Oblique/Transverse – AO/OTA 31-A3 | Moderate 1 study, N=39 Plate/Screw vs. IM | - No difference in patient outcomes between IF devices.; - No recommendation for device based on patient outcomes.

IF = internal fixation; IM = intramedullary device; THA = total hip arthroplasty

A strong case cannot be made for specific surgical treatments at this time for several reasons. Patient outcomes associated with different techniques produce only modest differences, if any. In addition, the literature does not include full complements of potential covariates which are necessary to draw clinically relevant conclusions. Moreover, the overall strength of the evidence, which we discuss in greater detail later in this chapter, is generally low. Finally, the literature comparing devices within a class is scant compared with device class comparisons themselves, which provide a weak foundation for suggesting any device class guidelines for the treatment of particular hip fracture patient populations.

Since surgical choices are not clearly differentiated by patient focused outcomes in the available literature, guidelines for surgical repair of hip fractures will need to rely on intermediate outcomes and expert opinion for the present time. The failure of the literature to provide guidance should not be viewed as an insurmountable problem, but rather, opportunities for research improvements. Later in this section we discuss recommendations for future research that, if followed, would provide firmer ground for future guideline updates.

The temporal nature of the recovery from hip fracture also bears more attention. The gain for patients seems to lie in the immediate post-treatment time spent in a better functional state. Among the two-thirds of patients who, on average, survive the first year after hip fracture, functional gains seemed to hit a maximum at 1 year.34 Clinical trajectories converge by this point, or even earlier. Patients who were followed longer than 1 year generally showed functional declines. The policy implications thus involve putting a value on what can be thought of as the area under the curve. What is the value of an improved short-term recovery if the benefits for one device relative to another are short lived? This question takes on greater importance as the population ages and the fracture risks increase. At the same time, there are growing numbers of young elderly patients still working, for whom a shorter recovery period may have a direct impact on their income potential.35

There is continuing focus in the surgical community on how best to treat displaced femoral neck fractures and unstable intertrochanteric fractures. Less investigation is directed toward nondisplaced femoral neck fractures, stable intertrochanteric fractures, particularly beyond early new implant investigations. Very little research has been aimed specifically at subtrochanteric fractures. The current femoral neck inquiries are somewhat more refined than those noted among intertrochanteric hip fracture patients in that the greatest controversy appears to be how to best treat displaced femoral neck fractures in the moderately old elderly patient.64 Surgeons appear to have a preference by device category for femoral neck fracture treatment, preferring internal fixation for physiologically young elderly patients, and arthroplasty for moderately healthy older patients (80 years or older), with no device consensus in between. Within those broad categories, there is no agreement on the use of specific devices. Surgeons need comparative outcomes information to inform their decisionmaking process about the implants they select, and their relationship to quality of life and mortality.64

## Applicability

Hip fracture has been deemed a marker of frailty. Given the high mortality rate in some patients, short-term gains in function within 3 to 6 months may be most pertinent in this elderly population. After 1 year, other comorbid factors may be primarily responsible for the functional declines noted. Although there is considerable interest in the lifespan of arthroplasty implants for elective joint replacement procedures, the questions of functional outcomes among elderly hip fracture patients treated with either arthroplasty or internal fixation may be best focused on shorter-range outcomes improvements.

Most orthopaedic study patients were community dwelling, cognitively-intact, independent ambulators prior to their hip fracture, making us unable to comment on how study factors relate to outcomes in nursing home patients. Other studies indicate that 20 to 30 percent of elderly patients who undergo surgery to treat a hip fracture in the United States fracture their hip while residing in a nursing home.9,65,199,200 Yet, few studies included nursing home patients, and all were non-U.S. study sites. Less than one-fourth of the studies included nursing home patients, who constitute at least 20 percent of all hip fractures patients,55 but did not distinguish them from non-nursing home patients in the analyses.

Patients with cognitive impairments, including dementia, were most often excluded from studies. Only three studies of femoral neck fracture patients included individuals with dementia. One was primarily a cost comparison of internal fixation versus THA.151 The authors suggested that reoperation rates were lower in patients with dementia due to lower functional demands, but mortality was higher among those with dementia, which is consistent with other nonorthopaedic studies. The other two studies had small patient samples (N=60 each) of cognitively impaired patients with displaced femoral neck fractures. The authors recommended, based on perioperative findings and failure rates, that internal fixation is the treatment of choice for patients with dementia, unless adequate reduction cannot be achieved. We cannot comment about which treatments are best for intertrochanteric hip fracture patients with at least moderate cognitive impairments from the existing literature.

A large proportion of patients were treated by surgeons in training at teaching hospitals. Since we cannot distinguish which cases were performed by residents in the existing literature, we cannot comment on any differences in mortality, function, or even intermediate outcomes such as reoperation or infection rates that may exist between patients of resident versus nonresident surgeons, given the current orthopaedic RCTs. Also, since studies tend to be conducted in high volume teaching centers, functional outcomes and mortality may differ among patients treated at nonacademic and lower volume centers that we are unable to account for within the current literature.

## Strength of the Evidence

Based on our review of the literature, the broader hip fracture outcomes questions of interest cannot be answered with existing RCT literature. Two main factors limit our ability to definitively answer the key questions posed in this study. The first factor is the limited perspective of discipline-specific investigations which commonly use an incomplete set of independent variables in study designs and models. The second factor is the generally low quality of hip fracture outcomes studies, where wide variability in the outcomes reported impedes aggregating, or even comparing, results.

The proliferation of outcome measures is not unique to hip fracture research. It can be found in other efforts that use musculoskeletal or neuromuscular function as an end point. For example, a recent Agency for Healthcare Research and Quality (AHRQ) technology assessment report on stroke rehabilitation also found a plethora of functional measures.201 Functional measures differ on several levels. They may be created by a discipline to assess condition-specific aspects. They may be generic. In either case, they may be used as a composite score (in which the internal value of components has been calculated statistically (psychometrically) or empirically, with or without a formal basis for item weighting) or subscales may be used. In some cases individual items are used to assess issues of specific interest, such as pain or walking ability. The scores may be derived from patient reports or professional assessments; the source can influence the result.202 Ultimately, the efforts to create consensus in the various research communities around generally accepted measures that adequately capture critical and relevant functional concepts will be broadly useful.

### Perspective

The key questions of this study involve broad analyses that should encompass several model components simultaneously, to determine how model factors affect outcomes among medically complex geriatric hip fracture patients. Current hip fracture outcomes conclusions are drawn largely from information derived from only a few model components at a time. Therefore, the resulting outcomes information lacks context and applicability within the greater realm of salient hip fracture outcomes. Moreover, the most commonly studied outcome is mortality, while perhaps more important and relevant outcomes, such as pain and function, are less frequently and more inconsistently addressed.

RCTs conducted by the orthopaedic surgeon community often focused on short-term process factors that were of interest to surgeons and the manner in which operations are carried out. Factors such as the type of fracture, operative treatment details, and short-term implant-related complications were often descriptively reported, with much less emphasis placed upon functional outcomes that are meaningful to patients. Very few outcomes were assessed from the patient’s perspective. Baseline patient data was often collected, but it was often an incomplete set of patient characteristics and subsequently not used in the analysis. Further, the full complement of other factors relevant to patients’ functional outcomes, such as inpatient protocols and rehabilitation, were not collected. Therefore, conclusions from the RCT literature regarding patient outcomes are tenuous at best.

Conversely, the observational literature, although replete with patient factors, often disregarded fracture type, fracture stability, and type of implant and assumed a homogeneous effect of these factors on functional outcomes. While these studies laid a solid foundation for further inquiry of patient factors because they relate to functional outcomes, the existing observational studies tend to overlook a large segment of U.S. hip fracture patients who are physically dependent, cognitively impaired, or both. Indeed, it is important to distinguish the clinical course of patients who fracture their hips in nursing homes, and are destined to return there, from those admitted from the community. The Mayo Clinic population-based studies were exceptions to this observation.9

### Study Quality

In general, although the orthopaedic study quality was low, it is improving, specifically within the last several years. We note both improvements in study conduct and improvements in the clarity of reporting, particularly in patient tracking and reporting post-discharge including better compliance with CONSORT recommendations.

This new initiative to improve outcomes reporting will likely result in the ability to link fracture type, pattern, and implant to outcomes only if well-designed, sufficiently powered trials with adequate followup and consistently used outcome measures are conducted. Better effort needs to be made to reassess debilitated elderly patients after acute inpatient stays in order to minimize nonmortality losses to followup. Unfortunately, the literature that was available for this review reflects a period of research prior to this effort and underlines the reasons for which the research community undertook improving research quality. The following discussion of the limitations of the literature can be used in a constructive manner to encourage the research community to continue the improvement trajectory that has already begun.

The most important factors within the RCTs that substantially limit the strength of the study conclusions are high and ambiguous patient attrition, inadequate power, inadequate or unreported randomization schemes, and poor comparability of outcome measures across studies.

High and ambiguous patient attrition. Attrition imposes two problems: (1) bias and (2) sample loss, which can affect power. Although mortality is known to be high among elderly hip fracture patients, it is important to distinguish death from sample loss. Mortality is an important outcome in its own right. It may be the ultimate functional outcome. Given a high mortality rate, many treatment advantages may be measured in terms of time in various functional states (i.e., months of improved function).

The reporting of losses to followup was poor and often difficult or impossible to determine. Studies commonly included inpatient mortality, but most lacked the number of patients analyzed per group at each followup time point after the acute inpatient stay. Few studies included the number of patients who followed up at intermediate assessment points, and many studies did not report the number of patients per treatment group that were assessed at the final followup. Instead, authors often reported intermediate and final outcomes as percent of cases, without clearly stating the actual number of patients examined per time point. The reasons for loss to followup were often vaguely reported, if at all, commonly mentioning “ill-health” as the reason for nonassessment. In other cases, the flow of patients through a study was reported by CONSORT statements, a very welcome recent improvement to study reporting in this literature. However, frequently the number of patients for whom functional outcomes were reported was not equivalent to the number of patients reported in the CONSORT statement, and the reason for the discrepancy was not reported. While mortality as a source of attrition is difficult to address, some investigators did take measures to minimize loss to followup through employing telephone interviews for patient assessed functional outcomes.

Another issue was investigator selection of analysis samples. Investigators often chose to exclude patients with implant failure or fracture nonunion from any further assessments and from all subsequent analyses. Analyses by subsamples of patients may be necessary to assess technical aspects of a device. However, if these subsamples are used for functional assessments, it may lead to biased results. Any subgroup analysis must be determined in advance and cannot be based on the outcomes.

Randomization issues. Randomization for surgical procedures for hip fractures, especially when many of the procedures are handled as emergency surgery events, is complicated by the fact that the surgeon may not have the full set of information necessary for clinical decisions until the surgery has begun. While an unavoidable complication, even with the best intentions, it leaves the door open for systematic bias to enter the randomization process. A number of studies reported randomization of patients prior to full application of exclusion criteria. For example, in some cases patients whose fractures were unable to be satisfactorily reduced were excluded after having been randomized to a study arm. Further, reporting of the randomization process itself was often cursory. About half of the studies reported the randomization scheme to be closed or in sealed envelopes. Only approximately one-quarter of included studies had information about sequence determination and implementation, which included randomization processes not recommended, such as basing randomization on medical record numbers or days of the week.

Other patient population issues. A large proportion of studies contained liberal inclusion criteria and minimal exclusion criteria, if any. Investigators with the stated or implied study focus of geriatric hip fracture patients often enrolled at least 10–20 percent of high energy trauma patients, those younger than age 50. Except in only a few studies, these patients were often not isolated in the analysis or by treatment group, likely due to problems with low power. A significant number of studies, particularly those prior to 1996, made no attempt to exclude patients with pathologic, cancer-related fractures, nor distinguish them in the analysis.

One important factor for determining inclusion criteria is identification of the fracture type and pattern. Surgeons used multiple fracture classification systems to identify fracture patterns, and the mapping of these patterns across classifications is not consistent. Additionally, surgeons show little reliability in their own ability to use these classification systems, which varies with surgeon experience and classification scheme.203 Since hip fracture patterns are varied and complex, nearly all studies aggregated multiple fracture subtypes based on the general stability of the collective fracture patterns to enable them to state conclusions about categories rather than subtypes of fractures. Often, this aggregation was needed, since certain fracture patterns are uncommon and few cases were available of some fracture subtypes despite long enrollment periods. For femoral neck fractures, the aggregation of subtypes into displaced or nondisplaced was highly consistent across studies, where Garden III-IV patterns were consistently labeled as displaced fractures.

In contrast, the aggregation of fracture patterns into stable or unstable categories within the intertrochanteric fracture studies was highly inconsistent and undermines many of the conclusions drawn that were based on fracture stability. Within the AO/OTA fracture classification system, (Figure 9 in Chapter 1) there are nine patterns of pertrochanteric fractures, and the frequency of each of fracture subtype is not evenly distributed. In the Fung et al. study, there was no consensus among surgeons about how to dichotomize the classifications into stable and unstable patterns.203 Thus, it is difficult to conclude if there was consistency in the stable versus unstable grouping of fractures within the existing RCTs, particularly among fractures in the mid-range of the intertrochanteric fracture classifications, the OA/OTA 31-A2 subtypes. Surgeons’ decisions to label fractures as unstable in RCTs when other surgeons would label them as stable fractures (i.e., AO/OTA 31-A2.1) artificially increases sample sizes when studying unstable fractures. Such sample size augmentation served to buffer the complication rates among fractures labeled as unstable, since the unstable treatment groups subsequently consisted of what other surgeons consider to be both stable and unstable fractures. In one study of unstable intertrochanteric fractures that included only AO/OTA 31-A2 fractures (three subtypes), two-thirds of patients had AO/OTA 31-A2.1 fractures, which are commonly considered to be stable fractures.117 This aggregation pattern was common among studies of unstable intertrochanteric hip fractures, and subtype grouping within any of the classification systems appeared to be investigator dependent.

Inconsistent baseline data were collected across trials, and even less were reported. The patient factors that were described in the methods section of each study often far exceeded what was included in the patient baseline information table. Patient age and gender were consistently reported. However, other factors known or believed to impact functional outcomes and mortality, such as level of pre-fracture function, race or ethnicity, fracture pattern, pre-fracture residence, cognitive impairment, injury mechanism, and comorbidities, were often not reported. Of particular note is the lack of race or ethnicity in patient baseline information.

Sample size and power. Few orthopaedic outcomes studies reported a sample size calculation or discussed power in relation to their primary study outcome. The average number of patients per study arm was approximately 75 patients prior to attrition, and the final number of cases analyzed was often not accompanied by a sample size calculation. The majority of studies lacked a sufficient number of cases to detect a clinically important difference between two treatment groups for a given outcome, even if one existed. In general, it appeared from discussion comments that many authors underestimated the magnitude of the attrition from high mortality and other losses to followup among frail, geriatric hip fracture patients. Also, the numbers of patients enrolled in RCTs are frequently too small to control for other factors (surgeon and hospital factors, rehabilitation site) on outcomes (function, mortality, pain, residence).

Inconsistency in functional outcomes. Table 3 in Chapter 3 clearly illustrates the idiosyncratic nature of outcome reporting that has historically predominated in the literature. Most of the outcomes reported in trials published prior to 2000 used only surgeon-reported outcomes. Many RCTs in this analysis did not report any functional patient outcomes. Of those with functional outcomes, many did not report group scores in a useable manner. Outcomes tables frequently lacked the number of patients in the analysis sample by group, or any identifiable measure of variation (range, standard error of the mean, standard deviation), impairing comparisons.

Other quality issues. We note a recent, positive shift in the style of outcomes reported in trials from exclusively surgeon-reported outcomes to both patient- and surgeon-reported outcomes. The benefits of using validated quality of life and outcomes assessment tools such as the SF-36, EQ-5D, WOMAC, and others is not yet fully reflected in the existing literature. Although we find this an encouraging sign, this trend is not yet consistent and appears to be investigator dependent.

Despite considerable efforts in the RCT literature to describe the technical aspects of performing hip fracture procedures, factors known to be both critical to the success of a procedure and surgeon dependent were often not reported. The degree to which fractures were realigned or reduced in relation to anatomic alignment, the extent to which the reduction held while an implant was placed, and the proximity of the final implant position to optimal were reported in a minority of studies. While the studies that included such details were explicit in doing so, few attempted to associate the quality of the reduction and implant position to implant failure or reoperation. None attempted to associate fracture or implant position to functional outcomes.

Surgeries performed by orthopaedic residents were common. A number of studies reported that residents performed all or most of the operative cases in the study.45,47,102,114,124,160,162,163 Another fifth of the studies used large numbers of surgeons, where experience level undoubtedly varies widely, or explicitly stated the staff included both junior and senior surgeons. When both experienced surgeons and residents performed cases, we most often could not tell which surgeries were performed by residents. Few studies separated outcomes by surgeon seniority.

General levels of surgical experience are commonly not reported, or are only reported descriptively and collectively, and not by treatment group. Surgeons’ experience with each device in a given study was rarely reported. This was particularly common in the intertrochanteric hip fracture studies, where intramedullary nails had previously been used for long bone fractures but were newly used for fractures of the hip. Many surgeons had no experience with intramedullary nails or only two to five cases prior to study participation, yet were reported to be accustomed to the plate/screws devices used in the other treatment arm. Specific familiarity with each device per surgeon was rarely reported.

Many RCTs tested newly introduced devices. However, once the initial new implant questions of complication rates, implant failures, and other post-operative complications, such as infection, were moderately addressed in comparison to an existing device, studies often failed to inquire further with additional studies to evaluate outcomes that are meaningful to patients. Equivalent complication rates do not necessarily equate to equivalent functional outcomes. Also, followup data can be misleading if critical groups are eliminated. Followup among patients who experienced implant failure was often incomplete or fully excluded from analyses. Not all patients with nonunion, implant failure, and device related pain underwent another surgery. Therefore, reoperation rates, particularly in this elderly patient population, likely underreport actual complication rates, since many older patients are too frail to undergo an additional procedure after their hip fracture surgery. Reoperation rates have also been shown to be subject to local variation, even within study protocols.185 It is important to report on the outcomes of patients who had postoperative orthopaedic complications but did not have additional surgery to correct the problem, since the RCT literature lacks information as to which complications most adversely affect postoperative function, particularly ambulation.

The effects of post-hospital therapy, including rehabilitation, were often excluded entirely from hip fracture RCT analyses. Most studies that briefly listed in-hospital mobilization protocols indicated that protocols were the same for both treatment groups but provided no further information regarding patients’ post-acute care. Most studies did not report the type, intensity, and duration of post-acute rehabilitation. Inpatient stays have shortened considerably in the United States in recent years, accompanied by an increased used of post-acute rehabilitation, which is not reflected in the RCT literature we reviewed. Also, nearly all RCTs were conducted in Europe, which reduces comparability to U.S. populations.

Current analysis practices allow too much room for both Type I and Type II errors in relating clinical characteristics and interventions to outcomes. Significance levels were often not corrected for multiple outcome comparison, which opens the door for finding significant differences in devices that could be purely due to chance. The study by Utrilla et al. is an example.92 Only one outcome was found to be significant at an unadjusted level. Had the outcome been adjusted to account for the possibility of significant difference in one out of seven outcomes purely by chance, there would have been no differences found between the devices. On the other hand, the small patient numbers previously mentioned, compounded with loss due to mortality and attrition, increase the likelihood of a Type II error, not finding a difference when there was one. While reporting of power calculations has been disappointingly low, the frequency of power calculation reports has increased in recent years.

Among studies that used existing assessment tools for THA patients, such as the Harris Hip Score, many patients scored below the lowest possible category (<70=poor) at all followup time points. Differences across treatment groups were often nonsignificant, which may be due to a lack of instrument sensitivity to minimal differences in highly disabled patients. Differences in mean values across treatment groups that were reported as statistically significant most often would not be expected to show relevant clinical differences.

Outcomes assessors were generally not blinded to the treatment, which increases the opportunity for biased assessment and reporting. Several recent studies identified that the functional assessors were not directly involved with the study, but only one study indicated that the patients remained clothed during functional assessment so the examiner could not determine from the incision which surgery a patient had undergone.

Finally, it was difficult or impossible to determine the degree of industry funding for many studies, particularly those prior to 2000. After that time, formal funding disclosure statements started to appear in articles from several major journals. Many studies appeared to be entirely unfunded works performed within one hospital or one academic center. Still, despite some disclosures of study funding, most did not contain specific details about the presence or absence of individual author’s consulting or design arrangements with device or bone cement companies.

## Recommendations for Future Research

Given the preceding discussion of the limitations of the current research literature, there are a number of recommendations which can be made to improve future research so that it might contribute to improved surgical guidelines in the treatment of hip fracture patients. Table 10 at the end of the chapter provides a summary of the research recommendations.

Table 10 Future research recommendations

Key Question | Results of Literature Review | Types of Studies Needed to Answer Question | Future Research Recommendation
1. What is the relationship between patient variables, the type of fracture) and post-treatment outcomes? | Age, gender, prefracture functioning, and cognitive impairment appear to be related to mortality and functional outcomes. | Comprehensive studies that include variables that describe salient patient characteristics, fracture type, and surgical factors | - Include nursing home or dementia patients and distinguish them in analysis.; - Include comprehensive set of predictor variables.; - Collaborate with surgeon investigators.; - Include stable/unstable intertrochanteric subtypes in analyses, as well as surgical treatments; does outcome depend more on reduction than implant?
2. What is the relationship between the type of fracture and post- treatment outcomes? | Fracture type is not independently related to patient outcomes in observational literature, but the literature has not generally examined stable and unstable intertrochanteric fractures. | Comprehensive studies that include variables that describe salient patient characteristics, fracture type, and surgical factors
3. What is the relationship between implant variables and patient post-treatment outcomes? | Few studies show dramatic effects on patient level outcomes. | Well-designed RCTs. Likely multicenter studies will be necessary to attain adequately powered sample sizes. | - Consistent use of validated outcome measures.; - Quantify and report quality of surgical technique.; - Reliable reporting of stable/unstable intertrochanteric fracture subtypes.; - More inclusive conceptual models.; - Data pooling.; - Collaborate with observational investigators.
4. What is the relationship between the type of intervention and patient post-treatment outcomes? | Few studies show dramatic effects on patient level outcomes. | Well-designed RCTs. Likely multicenter studies will be necessary to attain adequately powered sample sizes.

- Encourage collaboration between the research communities rooted in different research disciplines and methodologies. Bringing together the surgeon’s perspective with regard to the importance of fracture types and patterns and device/surgery specifics and the epidemiologist’s understanding of the importance of patient factors would move forward our comprehensive understanding of hip fracture patients and help match best treatments to the patient populations most likely to benefit from those treatments. A recent issue of The Journal of Bone and Joint Surgery published a series of articles addressing research design and potential contributions that well designed observational studies can provide to orthopaedic research.36–43
- Continue focusing on rigorous study design, sufficiently powered RCTs that follow CONSORT recommendations, and focus on patient relevant functional outcomes. Multicenter, well-designed RCTs are necessary to evaluate results among patients with uncommon fracture patterns. Firm inclusion and exclusion criteria should be specified before embarking on RCTs and be strictly followed throughout enrollment to minimize post-randomizations exclusions.
- Establish consensus on consistent definitions of stable and unstable intertrochanteric fractures within the most commonly used classification system(s). The use of obsolete classification systems should be avoided. At a minimum, the frequency of each fracture subtype among all patients should be included in all manuscripts and analyzed in relation to outcomes. This would not preclude authors from recommending refinement or switching to other classifications systems. But if recommendations are made in addition to, and perhaps compared with, a standard, the ability to leverage the information across research programs would be greatly enhanced.
- Develop more inclusive conceptual models. Surgical repair of hip fractures is a necessary critical step in restoring function to patients, but viewed in isolation it is insufficient. In order to isolate the effects of surgical treatments, research will need to incorporate measurements of all the major contributors to patient outcomes in order to control for them. Only a small portion of the published research for hip fracture surgical treatments collected such data, and even less incorporated the data into the analysis. Other patient characteristics important to understanding final outcomes may still need to be delineated. For example, fear of falling at 6 weeks post-surgery was a significant predictor of patient outcomes for hip fracture patients, in addition to cognitive impairment and depression.44 Patient outcomes may also be affected by the inference the patient draws from under-controlled pain and the contextual experience.
- Enhance the reporting of surgeon related variables. Define and quantify the quality of surgical techniques. As a few studies have begun to do, surgeons can quantify the quality of the fracture reduction postoperatively.45–47 Surgeons can also assess the technical quality of their implant placement immediately postoperatively.45,46,48,49 It would also be appropriate to identify and report surgeons’ levels of experience in general, and their specific experience with the devices and procedures used for an RCT and, if possible, use this information in the analysis.
- Consistently use validated quality of life and outcome assessment tools to improve comparability of outcomes across studies. A number of well-developed scales are available.50 Investigators do not need to resist the urge to tweak outcome measures if they discipline themselves to ensure that the measures idiosyncratic to their own study are accompanied by validated measures that ensure their studies will be available for pooling.
- Consider funding data pools wherever possible. This is particularly important for assessing infrequent events such as low frequency fracture patterns, specific complications, or patients who represent a small proportion of the overall patient base. The observational literature has taken the lead to date on pooling data across studies. For example, enough research exists to demonstrate gender differences in hip fracture risk factors and outcomes.11,51,52 Yet the research examined in this review found women to represent approximately 80 percent of the patient population across the studies. Within single studies this often does not provide sufficient power for subgroup analysis. Men that sustain a hip fracture are often sicker and are at higher mortality risk than women, and differentially develop complications and respond to treatment.51
- Include and report on patients with cognitive impairments and dementia, with particular emphasis placed on patients admitted from nursing homes or other institutional residences. The issue of best treatments for very frail elderly patients will only continue to grow as the general population ages.
- Include all patients in the analysis sample for functional outcomes, particularly patients who experienced device failures. Whether and how early failure affects long term outcomes remains an empirical question that cannot be answered if such patients are excluded.

Appendixes and evidence tables cited in this report are available at http://www.ahrq.gov/downloads/pub/evidence/pdf/hipfracture/hipfracture.pdf