# Results

## Search Results

The search string for RCTs generated 625 unique references, of which 81 articles, representing 76 unique trials, were retained. The articles break down into 35 trials for femoral neck fractures, 40 trials for intertrochanteric fractures, and one trial for subtrochanteric fractures. The literature is overwhelmingly international, with only five published trials originating in the United States. Of the 6,773 articles generated with the observational study search string, 144 articles were reviewed at the full text level, and nine observational studies were retained for key question 1. Observational studies tended to originate in the United States. The quorum statement is available in Appendix E. Excluded studies are shown in Appendix F.

There is an interesting imbalance in the literature. For both femoral neck and pertrochanteric fractures, there are very small numbers of articles at the extreme right of the decision tree/literature maps shown in Chapter 2, and much larger numbers of articles at the level of class comparisons. In other words, most head to head comparisons for hip fractures compare different classes of fracture repair devices when there is not supporting RCT literature to show equivalency of implants within the broader device classes. For example, a number of articles looked at some form of internal fixation versus some form of arthroplasty for femoral neck fractures, but few studies helped determine which forms of internal fixation were equivalent relevant to outcomes.

All the key questions relate some set of variables to patient post-treatment outcomes. The most widely reported variable by far was mortality, although functional outcomes and pain may be seen as more important and relevant outcomes. Table 3 at the end of Chapter 3 lists the patient outcomes, in addition to mortality, available in the RCT literature. The outcomes are grouped into functioning, quality of life, residence, and pain. With the exception of mortality, there are few instances where similar patient outcomes are used for similar patient populations being tested with the same device comparison, mainly due to inconsistent use of outcomes measures. There was inconsistent reporting of the data required for quantitative analysis, such as the number and percent of patients with each target outcome. Several articles, noted in Table 3 provided no data at all or only a simple summary statement in the text, usually when no difference was found in an outcome between groups. Other studies did not report necessary information, such as the analytic sample size used for the outcome, or some measure of the variation of the mean score.

Table 3 Patient outcomes used in literature

Outcome | Articles in Which Outcome was Used
Functioning – Femoral Neck
6 minute walk | Cornell, 1998^167^
Walking distance in miles | Baker, 2006^163^
Walking distance 1 kilometer or more | Jonsson, 1996^141^
Walking ability: no aid, with aids, not walking, unknown | Mjorud, 2006^45^ (no data)
Walking: 1 cane or less outdoors | Jonsson, 1996^141^
Walking: 1 or no aids, 2 canes or more, not ambulatory | Lagerby, 1998^145^
Walk without or 1 stick, walk with aid, not walking | Olerud, 1991^143^ (no data), Rehnberg, 1989^24^
Return to same walking aid use: none, walking stick, walking frame (Zimmer), immobile | Parker, 2002,^147^ Parker, 2000,^148^ Paus, 1986^25^ (no data)
Return to prefracture walking | Roden, 2003^146^
Independent of aids (no specifics) | Emery, 1991^162^
Mobility: Independent (does shopping), independent with aids, housebound unless accompanied, uses aids indoors, chair or bedbound | Ravikumar, 2000^129^ (insufficient data), Skinner, 1989^124^ (no data)
“Get up and go” | Cornell, 1998^167^
Activities of Daily Living (ADL) (no specifics) | Mattsson, 2006^150^
ADL independence on at least 5 functions | Blomfeldt, 2005,^152^ Blomfeldt, 2007,^166^ Blomfeldt, 2005^161^
Able to do own shopping | Jonsson, 1996^141^
Able to go shopping | Livesley, 1993^194^
Home assistance less than 4 hours weekly | Jonsson, 1996^141^
Oxford hip (global) | Baker, 2006^163^
Merle D’Aubigne mobility scale (passive, 6 increments of mobility) | Mattsson, 2006^150^ (no data)
Musculoskeletal functional assessment: mobility and ADL | Raia, 2003^164^ (insufficient data)
Parker/Palmer mobility score | Parker, 2002, 147 Parker, 2000^148^ (insufficient data)
Harris hip score (global) | Johansson, 2006^151^ (insufficient data), Davison, 2001^128^ (insufficient data), Johansson, 2000^157^ (insufficient data), Ravikumar, 2000^129^ (insufficient data), Kuokkanen, 1991^131^
Harris hip score subscales: pain, function, absence of deformity, range of motion | Blomfeldt, 2007^166^
Hip rating questionnaire. 100 point scale equal weight to global, pain, walking, function. | Keating, 2006^192^
Charnley score: pain, movement, walking | Blomfeldt, 2005^152^ (insufficient data), Blomfeldt, 2005^161^
Matta scoring system: (global) pain, ambulation, range of motion - surgeon rated | El-Abed, 2005^127^
Barthel index (based on ADLs, maximum score-20) | Davison, 2001^128^
Johansen hip score | Cornell, 1998^167^
PRRAFSWWAO: patient’s opinion of hip, rest pain, pain rising from chair, activity pain, hip flexion, ability to climb stairs, assistance walking, activity | Livesley, 1993^194^
Return to preinjury state (no specifics) | Davison, 2001^128^
Functioning - Pertrochanteric
Walking: able to walk without aids or 1 stick, walk with aids, walk when assisted by another person | Vidyadhara, 2007,^138^ Pajarinen, 2005^98^
Walking aids (no specifics) | Ahrengart, 2002^99^
Walking: no aid or 1 stick (%) | Adams, 2001^106^
Walking: no aids, aids, nonwalker | Lunsjo, 1999,^109^ Leung, 1992^122^
Walking: without help, with aid, wheelchair/bedridden | Janzing, 2002^104^
Walking: 0 – 6 scale from no support to bedridden/wheelchair | Park, 1998^110^
Walking 15 miles | Ekstrom, 2007^132^
Ambulation: community, community with aid, household | Goldhagen, 1994^118^
Recovery of walking to pre-op status (%) | Efstathopoulos, 2007,^134^ Pajarinen, 2005^98^
Return to pre-injury living (ambulation) status: community, household, nonambulatory | Harrington, 2002^102^
Return to independent walker (no specifics) | Olsson, 2001,^107^ Lunsjo, 2001^108^
Rise from chair without arm support | Ekstrom, 2007,^132^ Mattsson, 2005^97^
Climb a 15 cm curb | Ekstrom, 2007,^132^ Mattsson, 2005^97^
Katz ADL: A independent in all; B independence in all but one, C-G dependence in bathing and at least one other function | Miedel, 2005^46^
ADL scale (global) | Kim, 2005^140^
ADL individual components | Mattsson, 2005^97^ (no data)
Weight-bearing score (single leg) | Peyser, 2007^96^
Mobility scores (no specifics) | Efstathopoulos, 2007^134^
Harris hip score (global) | Vidyadhara, 2007,^138^ Kim, 2005^140^ Moroni, 2004,^95^ Schipper, 2004,^135^ Adams, 2001^106^ (insufficient data)
Salvati & Wilson score: pain, walking ability, muscle power- motion, overall function | Papasimos, 2005^91^ (insufficient data)
Parker & Palmer mobility score (global) | Utrilla, 2005,^92^ Hardy, 2003^139^ (insufficient data), Saudan, 2002,^100^ Sadowski, 2002,^69^ Hardy, 1998^112^
Parker & Palmer mobility subscales: hip pain, thigh pain, walking | Utrilla, 2005^92^
Charnley: pain, movement, walking ability (subscales) | Miedel, 2005^46^ (insufficient data)
Merle d’Aubigne: pain, walking, mobility subscales | Fritz, 1999^137^ (insufficient data)
Quality of Life – Femoral Neck
SF36 | Baker, 2006,^163^ El-Abed, 2005,^127^ Raia, 2003^164^ (insufficient data)
EQ-5D Euro-QoL | Keating, 2006,^192^ Blomfeldt, 2005^152^ (no data), Blomfeldt, 2007^166^ (no data), Blomfeldt, 2005^161^ (no data)
Quality of Life - Pertrochanteric
SF36 (global) | Moroni, 2004^95^
SF36 (subscales) | Mattsson, 2005^97^ (insufficient data)
EQ-5D (subscales) | Miedel, 2005^46^ (insufficient data)
Jensen social function | Hardy, 2003^139^ (no data), Saudan, 2002,^100^ Sadowski, 2002^69^
Residence – Femoral Neck
Residence: home, sheltered home, NH, hospital | Livesley, 1993^194^
Living condition: independent vs. NH | Mjorud, 2006^45^ (no data), Blomfeldt, 2007^166^
Living in own home | Lykke, 2003,^60^ Parker, 2002,^147^ Parker, 2000,^148^ Olerud, 1991^143^ (no data), Rehnberg, 1989^24^
Living situation: alone, with family, sheltered home | Emery, 1991^162^
Return to original residence | Roden, 2003^146^
Residence - Pertrochanteric
Living condition: own home, NH, institution | Ekstrom, 2007^132^ (insufficient data), Pajarinen, 2005^98^
Living condition: own home, not at home/institution | Utrilla, 2005,^92^ Ahrengart, 2002,^99^ Saudan, 2002,^100^ Sadowski, 2002,^69^ Adams, 2001,^106^ Fritz, 1999^137^ (insufficient data
Recovery of ability to pre-op level (%) | Pajarinen, 2005^98^
Accommodation (no specifics) | Hardy, 2003^139^ (no data)
Residence: independent, family/old people’s home, NH/hospital | Janzing, 2002,^104^ Lunsjo, 2001,^108^ Lunsjo, 1999^109^
Returned to own home | Ekstrom, 2007^132^ (insufficient data), Olsson, 2001^107^
Pain – Femoral Neck
VAS pain score | Mattsson, 2006^150^
Charnley pain score | Parker, 2002,^147^ Parker, 2000^148^ (insufficient data)
Little or no pain (no specifics) | Lykke, 2003^60^ (no data), Parker, 2002,^147^ Parker, 2000^148^ (insufficient data)
Degree of walking or passive joint motion pain (no specifics) | Lagerby, 1998^145^
No pain at rest | Jonsson, 1996^141^
No pain when walking | Jonsson, 1996^141^
No use of analgesics | Roden, 2003,^146^ Jonsson, 1996^141^
Pain/no pain (no specifics) | Emery, 1991^162^
Pain: none, on weight-bearing, constant | Olerud, 1991,^143^ Rehnberg, 1989^24^
Pain: no analgesics, occasional use, regular use | Ravikumar, 2000^129^ (insufficient data), Skinner, 1989^124^
Pain - Pertrochanteric
Hip pain (no specifics) | Vidyadhara, 2007,^138^ Utrilla, 2005,^92^ Baumgaertner, 1998,^47^ Leung, 1992^122^
Hip pain while walking (no specifics) | Hardy, 1998^112^
Thigh pain (no specifics) | Vidyadhara, 2007,^138^ Utrilla, 2005,^92^ Hardy, 2003,^139^ Leung, 1992^122^
Thigh pain while walking (no specifics) | Hardy, 1998^112^
Visual analog score (VAS) pain at rest | Ekstrom, 2007^132^ (insufficient data), Mattsson, 2005^97^
VAS pain initiating walking | Ekstrom, 2007^132^ (insufficient data)
VAS pain while walking (10, 50 feet) | Ekstrom, 2007^132^ (insufficient data), Mattsson, 2005^97^
VAS pain in single-leg stance | Peyser, 2007^96^
Hip or thigh pain: 4 levels, no pain to severe pain at rest requiring meds (continuous) | Saudan, 2002,^100, 69^
Resolution of hip pain | Hoffman, 1996^114^
Lateral pain over femoral head screw | Ahrengart, 2002^99^
Pain at top of greater trochanter | Ahrengart, 2002^99^

No data = article provided a summary statement regarding significance for the outcome, but did not provide supporting data

Insufficient data = article did not provide the full complement of data necessary for quantitative-analysis

## Key Question 1: What is the relationship between patient variables, the type of fracture, and post-treatment outcomes?

Key Question 1 examines the larger question of how patient characteristics, including fracture type, relate to patient outcomes. Key Question 2, which will be discussed next, focuses specifically on the relationship between fracture type and outcome, holding patient characteristics steady. (See Appendix E Table E1 for details on included observational studies.)

### Observational Literature

Very little research specifically addressed the link between patient characteristics and outcome variables by fracture type. As noted above, of over 6,700 articles screened, 144 articles were reviewed at the full text level, and only nine were retained. Because the observational literature is not centrally located and easily identified, as discussed in Chapter 2, we chose to use a search strategy that emphasized sensitivity to potentially relevant literature. The large majority of articles were excluded because they did not include all major fracture types or involved research questions that were not within the scope of this review. The majority of the articles that advanced to full text screening either did not perform a multivariate analysis, failed to include fracture type as an independent variable in the analysis, or used too small a patient sample. (See Appendix E quorum statement for more details.) Of the included articles, three involved research questions directly focused on examining the relationships between patient characteristics, fracture type, and outcomes, and the remaining six examined predictors of outcomes in general, of which fracture type was one possible predictor. Appendix E Table E1 provides details on the included studies. An additional eight articles found fracture type to be nonsignificant at the univariate level and did not advance the variable to the multivariate regression model.

Similar to the RCT literature, mortality was a predominant outcome. Two of the studies with focused research questions168,169 and two of the studies looked for general predictors of mortality as an outcome.82,170 For short term (4 to 6 month) mortality, one found increasing age predictive of mortality,170 two noted increased comorbidity,82,170 and three found lower prefracture functioning to be predictive of mortality following hip fracture.82,169,170 The only consistently reported predictor of short-term mortality was prefracture functioning. Age, male gender, heart failure, and intertrochanteric fracture were predictive of 10 year mortality.168 However; this study did not adjust for functional or cognitive status of the patients.

Functional outcomes were also reported in the majority of observational studies. Six studies evaluated 3 to 6 month short-term functional outcomes. Lower patient age and higher prefracture functioning were consistent predictors13,14,33,169–171 for recovery of functioning as measured by the ability to live independently, independence in activities of daily living (ADL)/independent activities of daily living (IADL), and mobility. Other identified predictors of functional recovery included lower ASA scores,33,170 living in the community at the time of hip fracture,82,170,171 and having a femoral neck, rather than intertrochanteric, fracture.171 Hannan et al.82 also found dementia to be a negative predictive factor if poor functioning and mortality were combined into an adverse outcome measure.

The same general pattern of predictive factors was found for functional outcomes at 1 year. Prefracture functioning14,33 and age13,14,33 remained consistently predictive. Koval et al,13 found that prefracture functioning, which was predictive for short-term functional recovery, dropped to nonsignificance at 1 year for recovery of ADL/IADLs. Intertrochanteric fracture type was found to be predictive of prefracture ambulatory patients becoming household or nonfunctional ambulators at 1 year.

These predictors for mortality and functional outcomes are consistent with observational studies that controlled for case mix variables, including fracture type.35,172–174 Penrod et al. also found that patients of white race were more likely to survive and walk independently at 6 months than nonwhite patients and that dementia was negatively correlated with functioning and survival.173 Studies that excluded fracture type from further analysis due to nonsignificance at the univariate level consistently found that increased age,175,176 male gender,11,176,177 reduced prefracture functional status,175,176,178,179 poor cognitive status,178,180 and more comorbidities or worse health indexes,175,176,179,180 were associated with higher mortality. Predictors of functional recovery included age,178 female gender,178 and prefracture functional status.178 Other investigators of hip fracture patient heterogeneity used cluster analysis to empirically differentiate hip fracture patients into multiple subgroups, identifiable through age, pre-fracture functioning status, and dementia.168,181,182

We used the conceptual model in Chapter 1 to assess the potential validity of the predictors found in the observational literature. The literature set did not include full complements of variables which may potentially contribute to patient outcomes. The first variable to note is adjustment for fracture patterns. Only one study adjusted for stable/unstable intertrochanteric fractures,169 one adjusted for number of fracture fragments for intertrochanteric fractures,170 and three adjusted for displaced/nondisplaced femoral neck fractures.11,168,170 The remainder of the studies used a dichotomous variable for femoral neck or intertrochanteric fractures.

There was inconsistent use of treatment factors as part of the overall modeling (see Table 4). Hospital factors tended to be addressed through the use of single hospital sites, although the assumption that patients were homogenous with regard to hospital factors would have been strengthened with the use of a measure of fidelity to inpatient treatment protocols. One study found slight differences in mortality and morbidity by hospital site, and suggested that hospitals may find the results a useful stimulus for quality improvement.170 Another study controlled for hospital site but did not report its contribution to the model.82 One study used detailed information on surgical treatment,170 and one dichotomized patients to internal fixation or prosthetic replacement.14 For the remaining two studies that reported surgical treatments for hip fracture patients,82,169 the information was collected at the aggregate level of device class, i.e., internal fixation, hemiarthroplasty, and neither could use the information in the analysis due to an almost perfect correlation between fracture type and surgical treatment. One study captured and included in the analysis some perioperative factors such as type of anesthetic.169 Neither surgeon factors nor rehabilitation factors appeared in any of the study analyses.11

Table 4 Treatment covariates found in observational research

Factors | Number of Articles that Collected the Factor | Number of Articles that Used the Factor in Analysis
Hospital factors | 2 | 2
Surgical treatment factors | 4 | 2
Perioperative factors | 1 | 1
Surgeon factors | 0 | 0
Rehabilitation factors | 0 | 0

### RCT Literature

No RCTs were designed to assess the association between patient or fracture variables and outcomes. Obviously, one cannot randomly assign risk factors. At best, investigators of RCTs would need to collect and use the necessary covariates to perform multivariate or stratified subgroup analyses. Table 5 provides a breakdown of the major classes of covariates, the specific factors within those major classes that were collected by the trials, and the number of trials that incorporated those specific factors into their analyses.

Table 5 Patient, hospital, and rehabilitation covariates from 81 RCT articles

Covariate Class | Specific Factor | Number of Articles that Collected the Factor | Number of Articles that Used the Factor in Analysis
Patient Covariates | Age | 65 | 4
| Gender | 65 | 3
| Mental status | 24 | 1
| Race | 1 | 0
| Fracture pattern | 51 | 2
| ASA status/health history | 24 | 0
| Obesity | 4 | 0
| Prefracture residence | 26 | 0
| Prefracture functioning | 44 | 0
| Prior fractures | 4 (often exclusion criteria) | 0
| Socioeconomic status | 1 | 0
| Smoking status | 0 | 0
| Alcohol use history | 1 | 0
Hospital Covariates | | 11 trials were multisite trials; 4 femoral neck, and 7 pertrochanteric. Of these 11, only 2 trials reported details regarding the sites; 1 femoral neck, and 1 pertrochanteric. | None
Rehabilitation Covariates | | None | None

Most hip fracture surgery RCTs are direct comparisons of implants, with minimum, if any, adjustment for patient characteristics. In a number of instances, potentially relevant information collected at baseline was not used further in the analyses. Only four articles adjusted their analysis by age,61,96,127,183 three by gender,61,127,183 one by the patients’ mental status,157 and two by fracture severity as determined by the number of bone fragments.61,108

Hospital factors within single trials are particularly important when the trial is a multicenter study. Of the 11 trials that were multisite,47,97,99,108,109,132,135,155,163,183,184 only two reported details regarding the sites135,183 and none used the data to adjust patient outcomes. One article provided an example of the importance of including other factors in analyses. Alho et al. performed a post- hoc analysis and found that the hospital site was more predictive of reoperations, an intermediate outcome, than the devices used in the trial treatment arms;185 a “hard” outcome, carefully defined and incorporated into the study design and protocol, was subject to local variation.

Essentially all articles briefly described their inpatient post-operative mobilization protocol. Most articles mentioned that all patients were encouraged to engage in early mobilization, perhaps supervised by a physical therapist, and that this inpatient protocol was the same for both treatment groups. No article collected the data, including fidelity to the post-surgical inpatient protocol, and incorporated it into their outcome analyses. Few articles mentioned discharge destination. Among those that did, none identified which patients went to some type of rehabilitation nor any details about the duration, type, or intensity of post-acute rehabilitation as it related to outcomes. For most articles, there were no comments about any special care provided after the acute inpatient hospital discharge.

The lack of comprehensive data collection within either the observational or RCT literature prevents a definitive answer about the relationship between patient characteristics, fracture types, and patient outcomes. Currently, the evidence suggests it is reasonable to treat age, gender, prefracture functioning, and comorbidities as predictors of hip fracture treatment mortality and functional outcomes, but other predictors may yet be found to be important.

## Key Question 2: What is the relationship between the type of fracture and post-treatment outcomes?

One observational study looked directly at the type of fracture relative to patient mortality and long-term recovery. Fox et al.186 examined mortality and recovery, defined as the return to prefracture level of independence, adjusting for significant prefracture characteristics, and found that patients with intertrochanteric hip fractures were less likely to recover functional abilities at 2 months, and had higher mortality at 2 and 6 months. However, by 1 year, recovery and mortality did not differ by fracture type. An increased likelihood of lower short-term 4 month recovery for patients with intertrochanteric fractures was also noted by Borgquist et al.171 Karagiannis et al.’s study found a long-term association by fracture type that intertrochanteric fractures were more likely to be associated with higher mortality over 10 years.168 However, the study did not adjust for prefracture functional status. Since functional status has been consistently found to be predictive of patient outcomes, the results of this study with regard to fracture type are questionable. In a subgroup analysis Koval et al.14 also found evidence that intertrochanteric hip fracture patients who were functional prior to fracture were more likely to become household or nonfunctional ambulators after fracture.

The majority of the other studies did not find fracture type to independently predict patient outcomes.11,13,14,33,82,169,170,173 Related observational research often found fracture type to be nonsignificant at the univariate or bivariate level and did not incorporate it further in the modeling.14,52,178,187 Many observational studies did not characterize patients by type of hip fracture.34,57,76,77,181,182,188–190

The observational literature provides a limited amount of evidence that overall, holding all other factors constant, type of fracture is not an independent predictor of long-term post-treatment patient outcomes. Cornwall et al. suggested, based on their study, that future prospective studies could treat all fracture types as a homogenous group.169 However, it is important to note that the authors acknowledge the uncertainty of stable and unstable intertrochanteric fracture classifications as a limitation. Until the lack of reliability in classifying unstable intertrochanteric hip fractures is addressed within the orthopaedic professional community, a definitive answer regarding the role of fracture types in post-surgical outcomes cannot be provided. Clarification of stable/unstable classifications should also help with confirming the limited evidence that intertrochanteric hip fracture patients experience delayed recovery patterns relative to femoral neck patients. The relative contribution of the impact of surgical treatment options on patient outcomes for intertrochanteric versus femoral neck fractures also remains unclear.

Similar to key question 1, the RCT literature does not allow for an analysis of the impact of fracture type on post-treatment outcomes. In order to isolate the impact of fracture type, the analysis would need to hold constant other factors which might affect patient outcomes, such as surgical treatment and both inpatient and outpatient rehabilitation protocols, and the literature is lacking in such covariates.

## Key Question 3: What is the relationship between implant variables and patient post-treatment outcomes?

Key question 3 relates to comparisons of devices at Nodes 3 and 4 of the decision tree/literature maps in Chapter 2. These nodes relate to differences between different devices within a device class, such as screws versus hook pins for internal fixation devices, or the choice to cement or not cement. (See Appendix E Tables E2-E5) for details on the included RCT studies.)

It is difficult to specifically separate the effects of the procedure/device from the setting/place of surgery without variables that account for factors closely related to the device and to the surgery itself. Results given in the sections for key questions 1 and 2 documented the limited use of hospital setting information. Surgeon and perioperative factors also contribute to the overall outcomes of a device and should be incorporated into analyses in order to isolate the effects of a device from the setting within which it was used. An example of this is a trial where two surgeons individually performed all surgeries for one arm of the study.105 In this situation it becomes impossible to separate the effect of the surgeon from the device.

Table 6 provides information regarding the number of times a surgeon factor was addressed in the literature and the number of times the factor was used in post-surgical outcome analysis.

Table 6 Surgeon factors reported in 81 RCT articles

Factors | Number of Articles that Collected the Factor | Number of Articles that Used the Factor in Analysis
Surgeon training/experience | 6 (4 FN, 2 IT) | 2^24,25^
Experience with device (learning curve) | 2 (all FN) | None
Any descriptive comment in text | 53 (22 FN, 31 IT) | None
Mentioned treatment arm is new | 6 IT | None
Defined learning curve | 4 (1 FN, 3 IT) | None
Study design well controlled for surgeons between arms (one or two experienced surgeons performed all operations) | 9 (5 FN, 4 IT) | None

FN = Femoral neck fracture; IT = intertrochanteric fracture

The large majority of articles made some descriptive statement in the text, most often reporting the number of surgeons involved, less frequently the surgeon training level, and infrequently the extent of experience a surgeon had with the specific devices used in the treatment arms. Very few articles provided an operational definition for “experience” with a device or experience in general.

The lack of comment about the surgeons’ experience or learning curve with new treatments is important to note. The articles which provided an estimate of the learning curve give a range of two to five cases as an adequate learning curve for the trial.60,92,103,135 Empirical data to support the claims are not provided. At least one author has suggested that the learning curve for second generation intramedullary nails is 25 cases.112 Because devices may have different learning curves, the overall lack of information is of concern.

Of the two articles that examined surgeon experience, one found that good positioning of the device was predictive of 1 year outcomes, and there was a trend for better implant position with greater surgeon experience.24 The other study did not examine post-treatment outcomes, but it also found that experienced surgeons took less time, had better results for fracture reduction and implant positioning, and their patients experienced fewer complications than among inexperienced surgeons.25 One study found that senior surgeons were more likely to have performed THA in one arm of the study, but did not adjust patient outcomes by surgical experience. In this study THA patients were found to have improved outcomes for displaced femoral neck fractures.

Ten studies also noted that large majorities of surgeries were performed by junior staff and residents.45,47,98,102,113,114,124,160,163,191 Still other studies had large numbers of participating surgeons with little information on experience level.60,96,108,109,132,151,157,192 When provided, the number of surgeons per study ran as high as 43.^132^ Several studies took care to mention that the residents were supervised by senior staff, although the extent of resident involvement in operative cases was not specified.47,113,114

Unlike surgeon factors, perioperative factors, such as operating time and type of anesthesia used, are frequently found in the literature, due to the fact that they are often reported as outcomes. Major and minor medical and device related complications are collected in great detail. Table 7 provides a list of selected perioperative factors found in the literature.

Table 7 Perioperative factors reported in 81 RCT articles

Factors | Number of Articles that Collected the Factor | Number of Articles that Used the Factor in Analysis
Time in surgery | 57 (16 FN, 41 IT) | None
Blood loss and transfusions | 51 (9 FN, 42 IT) | None
Anesthesia | 16 (2 FN, 14 IT) | None
Quality of surgical technique | 31 (14 FN, 17 IT) | None

FN = Femoral neck fracture; IT = intertrochanteric fracture

Quality of surgical technique includes evaluation of the surgeon’s reduction of the fracture in relation to anatomic alignment both before and after implant placement, and postoperative quantification of proper implant positioning in relation to optimal positioning as determined by prior clinical and biomechanical studies. While no article used surgical technique when investigating patient post-treatment outcomes, three studies used regression analysis to investigate the relationship between surgical technique and intermediate outcomes. The quality of surgical technique was not found to be related to the number of infections149 but inadequate fracture reduction and suboptimal implant position were associated with device failure130 and radiographic healing complications,61 and a higher need for revision surgery.46

We attempted to analyze the literature for final outcomes. Table 8 provides a breakdown of the number of studies within each comparison group that had extractable data. The table is organized by the levels of comparison illustrated in the decision tree/literature maps in Chapter 2. (See Appendix E Tables E6-E13 for specific outcomes by study.) Cells with relatively large numbers of reported functional outcomes include multiple forms of outcome measures (Table 3). Although the table is populated with only those studies that included extractable data, it should be noted that the number of empty cells and cells with low numbers in the table remains high even when including studies that provide insufficient or no data.

Table 8 Outcomes reported in studies by comparison group

Comparison | Pain (Categorical) | Pain (Continuous) | Functional (Categorical) | Functional (Continuous)
Femoral Neck
Node 4 Arthroplasty – Hemi choices | 1 | 0 | 2 | 0
Node 4 Internal fixation – Cemented vs. not | 0 | 0 | 0 | 0
Node 3 Arthroplasty – Uni vs. bipolar hemi | 0 | 0 | 1 | 1
Node 3 Internal fixation – Hook pins vs. screws | 1 | 0 | 0 | 0
Node 3 Internal fixation – Screws vs. screws | 1 | 1 | 2 | 1
Node 2 Arthroplasty – Hemi vs. THA | 0 | 2 | 1 | 4
Node 2 Internal fixation – Pins/screws vs. plate and screws | 0 | 0 | 0 | 0
Node 1 Internal fixation vs. hemi | 2 | 1 | 5 | 2
Node 1 Internal fixation vs. THA | 1 | 1 | 1 | 1
Node 1 Internal fixation vs. arthroplasty | 1 | 0 | 1 | 0
Intertrochanteric
Node 3 Plate/screw comparisons | 0 | 0 | 0 | 0
Node 3 Intramedullarynail comparisons | 1 | 0 | 0 | 0
Node 2 Plate/screw comparisons | 0 | 2 | 3 | 2
Node 2 Intramedullary nail comparisons | 0 | 1 | 2 | 3
Node 1 Plate/screw vs. Intramedullary nail | 6 | 2 | 9 | 4
Subtrochanteric
Node 1 | 0 | 0 | 1 | 0

### Mortality

Mortality was consistently gathered across the studies, and the relative risks for the studies reporting mortality data are provided here. The reader should recognize that mortality, while too frequent, is not necessarily a definitive outcome for hip fractures. The mortality data is followed by a brief narrative of the other patient outcomes based on what was reported in the literature.

Femoral neck fractures. For femoral neck fractures, Figures 9 through 11, provided at the end of the chapter, show forest plots of relative risks of mortality for unipolar versus bipolar hemiarthroplasties, screws versus hook pins, and sliding hip screws versus screws/pins, respectively. No significant differences are found in the relative risks for mortality in any comparison, nor are differences found across the different assessment periods. While the relative risk tends to be higher for patients receiving hook pins as compared to screws, the confidence intervals for all assessment periods still intersect the nonsignificance central line.

Figure 9 Femoral neck - mortality for node 3 unipolar vs. bipolar hemiarthroplasty

Figure 10 Femoral neck - mortality for node 3 internal fixation screws vs. hook pins

Figure 11 Femoral neck - mortality for node 2 internal fixation plate and screw vs. screw/pins

Intertrochanteric fractures. Figures 12 and 13 at the end of the chapter show forest plots of the relative risks of mortality among intertrochanteric hip fracture patients treated with types of implants within the same device class: various plate/screw models compared with each other (Figure 12) or different intramedullary nail models compared with each other (Figure 13). No significant differences were found between device subtypes within the broader implant classes for any assessment period. No differences were found in mortality for regular versus dynamic distal locking techniques (RR [relative risk] 1.35, CI [confidence interval] 0.56; 3.26),139 or cemented screws (RR 0.64, CI 0.11; 3.69).97

Figure 12 Intertrochanteric – mortality for node 2 plate/screw comparisons

Figure 13 Intertrochanteric – mortality for node 2 intramedullary device comparisons

### Pain and Functional Patient Outcomes

Femoral neck fractures. One small study (N=53) examined whether cemented or uncemented stems for hemiarthroplasties performed better for displaced fractures.162 Only active, pre-fracture independently mobile patients were included in the study. Identical stems were used for both treatment arms. More pain and use of walking aids continuing past 1 year after surgery was found among patients with uncemented stems. Miyamoto et al.27 suggested that evidence is tending to support cemented devices. However, this must be weighed against the harm study by Christie et al., which found greater and more prolonged embolic cascades during surgery for cemented hemiarthroplasties as compared to uncemented.165 This study involved only 20 patients with femoral neck fractures and provided little patient data with which to assess the appropriateness of the study. Since actual pulmonary embolism events are relatively infrequent, it would take considerably higher numbers of patients to understand the adverse event potential. A partial randomized study also switched its protocol from uncemented to cemented stems after complaints of hip pain.193

A comparison of hemiarthroplasty devices, one with a hydroxyapatite ceramic coated prosthetic stem versus a press-fit hemiarthroplasty (no ceramic coat) was examined in one study.194 Hydroxyapatite ceramic is used to secure fixation because it incorporates directly into bone in an effort to avoid the use of cement for stem fixation within bone. The study found reduced pain, improved walking ability, and less use of walking aids in patients with displaced fractures treated with the ceramic coated stems when compared with uncemented hemiarthroplasty. A more telling comparison may have been against a cemented hemiarthroplasty device.

Two studies examined unipolar versus bipolar hemiarthroplasty.164,167 No differences between the forms of hemiarthroplasty were found in mobility, functioning, or quality of life. Miyamoto et al.27 suggests that there is some evidence for bipolar hemiarthroplasty to be superior to unipolar forms, but that the difference may not be sufficient to justify the increase in cost.

For internal fixation devices, cemented versus noncemented screws were addressed in two trials.150,153 Both trials involved relatively healthy and active elderly patients with displaced fractures due to low energy trauma, but only one trial collected patient outcomes. No significant advantage was found for the cemented screws versus noncemented screws. Bajammal et al’s. systematic review,195 which included the two hip fracture trials in a larger set of more inclusive fractures, found that patients with cemented internal fixation devices had less pain during healing.

Comparisons of different forms of screws were addressed in two trials.24,145 Both trials involved inclusive sets of femoral neck fracture patients, allowing both displaced and nondisplaced fractures, and very limited exclusion criteria. Pain, the use of walking aids, and residential status were measured. One study found that one form of screws was related to less pain and lower use of walking aids in the short term (4 months); however, the same study also found a trend in surgeon experience to be predictive of outcomes.24 Published systematic reviews have not found superior performance related to specific numbers or forms of screws.196,197

Four trials compared two hook pins to two or three screws.45,60,142,143 This literature set also used relatively liberal patient inclusion criteria. The three articles that reported patient age ranges included patients as young as their late 20s. High energy trauma and bilateral fractures were also noted. The most relevant exclusion criterion was the exclusion of fractures which could not be satisfactorily reduced. Pain, the use of walking aids, and living situation outcomes were reported. One of three studies found more pain with the hook pins and among institutionalized patients.143 It should be noted that in the study which found more pain, the hook pin was a new device for the surgeons in that study, who also preferred the screws. Thus, neither screws nor hook pins were found to be consistently superior to the other,197 although screws have been found to be superior to hook pins with regard to overall complication rates.196

Four trials compared sliding hip screws (SHS) to either hook pins or screws for femoral neck fractures.25,61,125,130 Few patient exclusion criteria were used, although all but one article involved patient populations 50+ years of age. The only patient outcome reported across studies was mortality, and that was inconsistently reported across assessment periods. Neither SHS nor pins/screws were found to be superior with regard to patient outcomes in systematic reviews.196,197

Overall, the RCT literature for femoral neck fractures at comparison Nodes 3 and 4 does not offer evidence to suggest that a particular device is superior to other internal fixation devices with regard to patient post-treatment outcomes. This assessment supplements Parker et al’s.196 systematic review that recommended screws versus pins based on overall complication rates.

Intertrochanteric fractures. One study reported patient outcomes for a comparison of calcium phosphate cemented screws used to anchor a plate/screw system versus uncemented screws.97 Pain, quality of life, functioning. and the use of walking aids were reported at 6 weeks and 6 months. Lower pain and better functioning and quality of life were reported at 6 weeks, but by 6 months, only quality of life remained significant. Likewise, hydroxyapatite cement was tested in another study as a way to affix a plate/screw system.95 Harris hip scores and the SF36 were used to measure pain, mobility, and quality of life at 6 months for patients with unstable fractures. The augmented group had better Harris hip scores at 6 months.

One study examined static versus dynamic locking techniques for intramedullary hip screws (IMHS), a type of intramedullary nail.139 Patients had hip fractures that involved the medial femoral cortex or reverse oblique fractures. No differences were found between the groups for mobility or pain within the first year after surgery.

Six studies compared various forms of extramedullary plate/screw devices.96,103,104,107,108,113 The studies pitted SHS against a newer plate/screw device, such as the Medoff system. No differences were found in mobility, post-acute residential status, or ambulation. Pain was lower for percutaneous compression plates for 1 to 6 weeks after surgery in two studies,96,104 but this difference became nonsignificant for later assessment periods. Likewise, in one study patients were quicker to weight-bear after surgery, but there were no differences between groups for walking ability or residential situation at any later assessment periods.108

Five studies compared Gamma nails against some other form of intramedullary nails, of which four studies examined patient outcomes.134,135,137,138 None found any differences in mobility, functionality, or pain at any assessment period.

Subtrochanteric fractures. One study specifically examined extramedullary devices for subtrochanteric fractures.109 The study randomized patients to receive either a SHS, SHS with a trochanteric stabilizing plater, or a dynamic condylic screw, based on the surgeon’s decision, or the Medoff plate system. Outcomes were the use of walking aids and residential status, assessed at 4 and 12 months. Patients with the Medoff system were quicker to bear weight after surgery, but there were no differences in patient outcomes.

The findings of the studies are consistent with other systematic reviews which have not found evidence to suggest that one form of device within a class is superior to another, either plate/screw devices29 or intramedullary nails.72

Overall, given the mortality analysis and narrative of other patient outcomes, there is no evidence to support the use of one device over another within a class of devices for either femoral neck fractures or intertrochanteric fractures with regard to patient post-treatment outcomes.

## Key Question 4: What is the relationship between the type of intervention and patient post-treatment outcomes?

Key question 4 relates to comparisons of devices at Nodes 1 and 2 of the decision tree/literature maps in Chapter 2. These nodes relate to differences between different device classes.

As Table 8 showed in the last section, except for mortality, there were too few consistently measured patient outcomes to allow a quantitative analysis of classes of implants. Reporting of mortality data is again followed by a narrative report of other patient outcomes found in the literature.

### Mortality

Femoral neck fractures. Figures 14 through 16 are forest plots of the relative risks of mortality for hemiarthroplasty versus THA, internal fixation versus hemiarthroplasty, and internal fixation versus THA, respectively. The studies included in Figure 17’s forest plot include only those studies that randomized patients to an unreported set of arthroplasty options184 or randomized patients to receive either internal fixation, hemiarthroplasty, or THA.124,129,192 In all cases, there were no significant differences between groups in relative risk for mortality for any assessment period.

Figure 14 Femoral neck – mortality for node 2 hemi vs. total hip replacement

Figure 15 Femoral neck – mortality for node 1 internal fixation vs. hemiarthroplasty

Figure 16 Femoral neck – mortality for node 1 internal fixation vs. total hip replacement

Figure 17 Femoral neck – mortality for node 1 internal fixation vs. arthroplasty

Intertrochanteric fractures. Figures 18 and 19 are forest plots of the relative risk for mortality among patients treated with plate/screw devices versus intramedullary nails. Figure 18 contains studies that included all intertrochanteric fracture types; Figure 19 has studies that included only unstable fractures. There were no significant differences between groups in the relative risk for mortality for any assessment period. Figure 20 shows that this conclusion holds true for internal fixation versus hemiarthroplasty comparisons for patients with unstable intertrochanteric fractures as well.

Figure 18 Intertrochanteric – mortality for node 1 plate/screw vs. intramedullary nail

Figure 19 Unstable intertrochanteric – mortality for node 1 plate/screw vs. intramedullary nail

Figure 20 Unstable intertrochanteric – mortality for node 1 internal fixation vs. hemiarthroplasty

Subtrochanteric fractures. Figure 21 provides a forest plot of the relative risk for mortality for studies that explicitly included subtrochanteric fractures as defined by the study investigators. These studies compared plate/screw devices versus intramedullary nails,46,69,115,118,132 or one specific form of plate/screw device against another.109 Again, no significant differences were found in the relative risk of mortality between groups at any assessment period.

Figure 21 Subtrochanteric – mortality for plate/screw comparisons

### Pain and Functional Patient Outcomes

Femoral neck fractures. Two studies compared hemiarthroplasty to THA for displaced femoral neck fractures.163,166 One study used a followup period of 1 year and found that patients with THA had less pain than those who received hemiarthroplasty.166 The second study used a longer followup period of 3 years and found that compared to patients who received hemiarthroplasty, patients who received THA continued to show better functioning at 3 years.163 The patient populations in both studies were relatively healthy elderly patients living independently prior to the fracture.

Eight studies compared internal fixation with hemiarthroplasty, both cemented and uncemented versions, for displaced femoral neck fractures.120,127,128,146,147,149,160,161 The studies were relatively long term, ranging from 2 to 5 year followup periods. All but two reported a wide range of patient outcomes.149,160 Three studies reported better patient outcomes for internal fixation, including functioning and quality of life.120,127,161 Two studies reported that patients who received hemiarthroplasty were more likely to be satisfied with their recovery,128 regained prefracture functioning, and were free of pain faster than those patients who received internal fixation, although the differences found in these two studies became nonsignificant in later years146 One study found no difference between groups.147

Two internal fixation versus hemiarthroplasty studies specifically focused on patients over age 70 with cognitive impairments.149, 161 One study found a decrease in overall quality of life by the second year in hemiarthroplasty patients,149 while no differences were found in the other.161

Four studies compared internal fixation to THA for displaced femoral neck fractures.141,151,152,198 All studies found patients who received THA had better mobility, less pain, and better functioning and quality of life for at least 1 year following surgery. By the second year two studies found these differences to be moving to borderline significance,141,157 and the one study that continued to follow patients for 4 years also found the difference to have returned to nonsignificance.152

Three studies compared all three major forms of implants, either in individual arms of internal fixation versus hemiarthroplasty versus THA,124,192 or internal fixation versus an arthroplasty arm that included both hemiarthroplasty and THA.184 In general, THA was found to perform better than internal fixation with regard to mobility and pain. One study also found that patients with THA scored higher on quality of life measures compared to patients who received hemiarthroplasty.192

The patient populations for internal fixation versus hemi or total arthroplasty studies were almost exclusively relatively healthy, independently living elderly patients. The one study that specified dementia patients as the study population did not report patient outcomes.149

Overall, on the surface it would appear that THA tends to have improved patient focused outcomes over internal fixation, and authors of systematic reviews have suggested the evidence is strong enough to recommend THA for cognitively intact, independent elderly hip fracture patients.26,27 However, one systematic review found no difference in pain or functioning between patients who received internal fixation and patients who received arthroplasty.28 The question remains whether these positive findings for THA would continue to hold if the analysis included all the variables relevant to understanding patient outcomes.

Intertrochanteric fractures. Twenty-two studies compared plate/screw fixations to intramedullary nails for intertrochanteric hip fractures; 16 studies included both stable and unstable fracture patterns,47,92,98–100,106,110,112,114–116,118,119,121–123 and six studies included only fractures labeled as unstable by authors.46,69,91,94,102,132 Of these, five studies did not report any patient outcomes beyond mortality.94,115,116,119,121 The large majority of studies followed patients for 1 year or less. Two studies found reports of higher pain for intramedullary nails at final followup.99,112 Four studies found improved early mobilization or early weight bearing for intramedullary nails, but these gains were only in the very short term.112,114,122,132 Two other studies found improvements in mobility at 4 months,98 or 1 year92 for intramedullary nails, but these significant findings become nonsignificant when the appropriate Bonferonni significance corrections for multiple outcomes were conducted. The paucity of significant findings would suggest that with regard to patient outcomes, neither plate/screw implants nor intramedullary nails can be claimed to be superior over the other. There is some disagreement within the systematic review literature as well. The Cochrane reviews have supported SHS as superior to intramedullary nails for both stable and unstable fractures,29,30 while Kregor et al.31 argue that intramedullary nails are preferable for unstable fractures, specifically AO/OTA A3 fracture patterns. This may well be unable to be fully resolved until there is reliable agreement with regard to the classification of stable and unstable fractures. Kaplan et al.32 suggest there is insufficient evidence to support recommendations at this time.

Appendixes and evidence tables cited in this report are available at http://www.ahrq.gov/downloads/pub/evidence/pdf/hipfracture/hipfracture.pdf