# Methods

## Search Strategy

Our study search plan included electronic and manual searching. We searched a variety of electronic sources, including MEDLINE^®^, Cochrane databases, Scirus, and ClinicalTrials.gov. The electronic searches were performed on April 28, 2008, and included English language articles from 1985 to the present. We also manually searched reference lists from published systematic reviews.

The main search strategy included a list of terms intended to identify all research publications associated with two domains; intertrochanteric/subtrochanteric and subcapital hip fractures and types of implant interventions. We used key words relevant to the two domains as the search basis for all key questions. (The search strategies are provided in Appendix C). Comparison to MeSH headings found that all references identified with MeSH headings were subsumed in the keyword searches. We used a tested search filter designed to identify methodologically high quality randomized controlled trials.86

For key questions 1 and 2 a search filter designed and tested for identifying observational studies was coupled with the hip fracture domain search terms.87 Because observational articles are difficult to distinguish in electronic searches, this search was supplemented with additional searches using epidemiology, recovery, and odds ratio MeSH headings and keyword terms.88 Articles were also contributed from personal files of the authors and TEP members.

## Eligibility

For the randomized controlled trial (RCT) literature, two investigators independently reviewed article abstracts for eligibility using screening forms developed on Trialstat’s Systematic Review Software (SRS). (The forms are provided in Appendix D.) Screening was performed at two levels. The first screen used a more liberal approach and relied on title and abstract review. The second level examined full articles with a strict approach if (1) the article passed through the broad screening, (2) there were no abstracts, or (3) there was disagreement between the investigators on article eligibility. Differences of opinion regarding eligibility were resolved through consensus adjudication. We excluded external fixators as a class.

Patient population inclusion criteria were 50 years or older with nonpathologic fractures from low energy trauma, and an index fractures. Strict exclusion criteria were originally pathologic, bilateral, nonindex, and high energy trauma fractures. A more liberal approach to patient populations was allowed when we found that the literature is quite wide ranging in its use of exclusion criteria. The deviations a study made from the strict exclusion criteria for the review were noted.

Implantable devices for internal fixation used in included RCTs must have been available for use in the United States or be similar enough to U.S. devices that the results were meaningful. The excluded devices are either experimental or no longer in clinical use in North America. All retained devices have characteristics which are generally the same as implants which remain in use in North America. All devices were reviewed by clinician authors for inclusion/exclusion status. Decisions were based on clinical experience and/or examining specifications and images of the device in question. Opinions from TEP members were sought and TEP members vetted the final list. Articles examining head to head comparisons of internal fixations must compare included devices to be retained. The final list of included devices is provided in Table 2 at the end of the chapter.

Table 2 Included devices

Included Device | Included RCT Articles in which Device was Tested
Extramedullary
Sliding hip screw (SHS) includes Dynamic Hip Screw (DHS), Compression Hip Screw (CHS) | Papasimos, 2005,^91^ Utrilla, 2005,^92^ Mattsson, 2004,^93^ Pajarinen, 2004,^94^ Moroni, 2004,^95^ Peyser, 2007,^96^ Mattsson, 2005,^97^ Pajarinen, 2005,^98^ Ahrengart, 2002,^99^ Saudan, 2002,^100^ Brandt, 2002,^101^ Harrington, 2002,^102^ Kosygan, 2002,^103^ Janzing, 2002,^104^ Dujardin, 2001,^105^ Adams, 2001,^106^ Olsson, 2001,^107^ Lunsjo, 2001,^108^ Lunsjo, 1999,^109^ Park, 1998,^110^ Madsen, 1998,^111^ Hardy, 1998,^112^ Baumgaertner, 1998,^47^ Watson, 1998,^113^ Hoffman, 1996,^114^ Elmerson, 1995,^61^ Butt, 1995,^115^ O’Brien, 1995,^116^ Stappaerts, 1995,^117^ Goldhagen, 1994,^118^ Aune, 1994,^119^ van Vugt, 1993,^120^ Radford, 1993,^121^ Leung, 1992,^122^ Bridle, 1991,^123^ Skinner, 1989,^124^ Madsen, 1987,^125^ Linde, 1986^126^
SHS used in femoral neck studies | El-Abed, 2005,^127^ Davison, 2001,^128^ Ravikumar, 2000,^129^ Benterud, 1997,^130^ Kuokkanen, 1991,^131^ Paus, 1986^25^
DHS with Trochanter Stabilizing Plate (TSP) | Lunsjo, 2001,^108^ Lunsjo, 1999,^109^ Madsen, 1998^111^
Gotfried Percutaneous Compression Plate (PCCP) | Peyser, 2007,^96^ Brandt, 2002,^101^ Kosygan, 2002,^103^ Janzing, 2002^104^
Medoff sliding plate (multiple versions with different numbers of holes) | Ekstrom, 2007,^132^ Miedel, 2005,^46^ Olsson, 2001,^107^ Lunsjo, 2001,^108^ Lunsjo, 1999,^109^ Buciuto, 1998^133^
Dynamic Condylar Screw (DCS) (95 fixed angle plate) | Sadowski, 2002,^69^ Lunsjo, 2001,^108^ Lunsjo, 1999^109^
Minimally invasive percutaneous plate osteosynthesis (MIPPA) using DCS | Dujardin, 2001^105^
Intramedullary
Gamma nail (first, second, third generation) | Efstathopoulos, 2007,^134^ Miedel, 2005,^46^ Schipper, 2004,^135^ Herrera, 2002,^136^ Ahrengart, 2002,^99^ Adams, 2001,^106^ Fritz, 1999,^137^ Madsen, 1998,^111^ Hoffman, 1996,^114^ Butt, 1995,^115^ Goldhagen, 1994,^118^ Aune, 1994,^119^ Radford, 1993,^121^ Leung, 1992,^122^ Bridle, 1991^123^
Asian Gamma nail, or Gamma AP | Vidyadhara, 2007,^138^ Park, 1998^110^
Intermedullary Hip Screw (IMHS) | Hardy, 2003,^139^ Harrington, 2002,^102^ Hardy, 1998, 112 Baumgaertner, 1998^47^
Proximal Femoral Nail (PFN) | Ekstrom, 2007,^132^ Papasimos, 2005,^91^ Kim, 2005,^140^ Pajarinen, 2004,^94^ Pajarinen, 2005,^98^ Schipper, 2004,^135^ Herrera, 2002,^136^ Saudan, 2002,^100^ Sadowski, 2002^69^
Gliding nail | Fritz, 1999^137^
ACE trochanteric nail | Vidyadhara, 2007,^138^ Efstathopoulos, 2007^134^
Femoral Neck Multiple Implants
Hansson hook pin (LIH pin) (6.5 mm smooth pin with hook extruded at tip) | Mjorud, 2006,^45^ Lykke, 2003,^60^ Elmerson, 1995,^61^ Jonsson, 1996,^141^ Herngren, 1992,^142^ Olerud, 1991^143^
Thornton nail (flanged trifin cannulated nail) | Jacobsson, 1985^144^
Uppsala screws (8 mm cancellous screw with 6 mm shank) | Lagerby, 1998,^145^ Herngren, 1992,^142^ 662, 675
Von Bahr screws (7 mm cancellous screw with 5.5 mm shank) | Roden, 2003,^146^ Rehnberg, 1989,^24^ Paus, 1986^25^
Mecron screws | Kuokkanen, 1991^131^
AO screws | Mjorud, 2006,^45^ Parker, 2002,^147^ Parker, 2000,^148^ van Dortmont, 2000,^149^ Madsen, 1987,^125^ Linde, 1986^126^
Olmed screws (6 mm shank and 8 mm threads) | Mattsson, 2006,^150^ Johansson, 2006,^151^ Blomfeldt, 2005,^152^ Mattsson, 2003,^153^ Tidermark, 2003,^154^ Tidermark, 2003,^155^ Johansson, 2001,^156^ Johansson, 2000,^157^ Bachrach-Lindstrom, 2000,^158^ Benterud, 1997,^130^ Neander, 1997^159^
Ullevaal screw (7 mm shank and 7 mm cancellous thread) | Lykke, 2003,^60^ Puolakka, 2001,^160^
Scand pin (6.5 mm cancellous threaded screw) | Jacobsson, 1985^144^
“Cannulated screws” (Depuy/J&J) | Blomfeldt, 2005^161^
Richards screw (4.8 mm shaft 6.86 mm thread) | Lagerby, 1998^145^
Hemiarthroplasty
Thompson unipolar (cemented and uncemented) | Puolakka, 2001,^160^ Davison, 2001,^128^ van Dortmont, 2000,^149^ Emery, 1991^162^
Endo femoral head (Zimmer) with Zimmer CPT stem | Baker, 2006^163^
Unitrax unipolar | Raia, 2003^164^
Centrax bipolar | Raia, 2003^164^
Moore unipolar (uncemented) | Skinner, 1989^124^
Austin Moore unipolar (uncemented) | El-Abed, 2005,^127^ Blomfeldt, 2005,^161^ Parker, 2002,^147^ Ravikumar, 2000,^129^ Christie, 1994,^165^ Emery, 1991^162^
Monk bipolar (cemented) | Davison, 2001^128^
Varikopf bipolar | Roden, 2003^146^
Mallory head calcar replacement system | Kim, 2005^140^
Vandeputte (VDP) endoprosthesis | Stappaerts, 1995^117^
Bipolar Stanmore variocup | Van Vugt, 1993^120^
Exeter modular stem (28 mm head, OGEE acetabular component) bipolar hemi or total hip replacement | Blomfeldt, 2007,^166^ Blomfeldt, 2005,^152^ Tidermark, 2003,^154^ Tidermark, 2003^155^
ODC modular femoral components | Cornell, 1998^167^
Total Hip Replacement
Charnley system | Jonsson, 1996^141^
Zimmer system (acetabular cup with CPT stem) | Baker, 2006^163^
Lubinus system | Johansson, 2006,^151^ Johansson, 2001,^156^ Johansson, 2000^157^
BiMetric | Neander, 1997^159^
Howse II | Ravikumar, 2000,^129^ Skinner, 1989^124^

Because the studies generally do not differentiate type of femoral neck fracture, we included all types of intracapsular fractures, including subcapital, transcervical, and basicervical areas of the femoral neck and provide results both undifferentiated and differentiated where possible. By convention, factures of the femur up to 5 cm below the lesser trochanter are subtrochanteric fractures. This category also includes hybrid intertrochanteric fractures with subtrochanteric extensions.

Based on a meta-analysis which showed nonrandomized studies generated biased estimates for mortality risk and relative benefits for hip fracture devices,89 the review was limited to randomized controlled trials for key questions 3 and 4. Only full journal articles were included. Trial results reported in brief abstracts do not have the space necessary to report on all the factors a comprehensive approach to patient outcomes requires. Articles were not excluded based on country of research origin.

Quasi-experimental articles used for key questions 1 and 2 were limited to cohort studies with prospectively collected data and some form of multivariate analysis. Both femoral neck and pertrochanteric fractures needed to be included and fracture type entered as a factor in the multivariate analysis. Patient populations needed to be at least 200 to allow for sizeable enough numbers in each analysis group, which can be quite numerous when crossing multiple patient characteristics, fracture types and patterns, and outcome measures. Included studies were required to specifically involve research questions aimed at understanding the relationship between patient characteristics, fracture type, and patient outcomes. Titles and abstracts were screened using Endnote files; a file was coded only if it was potentially includable based on the inclusion criteria. This approach was utilized due to the significant size of the data files, over 6,700 articles. Full text was pulled for all potentially included articles and coded for inclusion or reason for exclusion. As this resulted in a very limited set of includable articles, the literature was supplemented with a comprehensive but not exhaustive representative set of articles aimed at understanding the relevant patient populations and outcomes through analysis of other factors of care.

## Data Extraction

At least two researchers independently abstracted each included article using a standard abstraction form created on SRS (Appendix D). We generated a series of detailed evidence tables (Appendix E) containing all the relevant information extracted from eligible studies. Results of the evidence tables were used to prepare the text of the report and selected summary tables. At least two researchers checked the quality of each evidence table. Differences were resolved through consensus.

## Data Analysis

Decision-tree/literature maps, shown in Figure 7 for femoral neck and Figure 8 for intertrochanteric/subtrochanteric fractures, were developed based on the available literature. Reading from left to right, the maps are very simplified decision trees modeling a surgeon’s possible decision choices regarding which device to use. Reading from right to left, the maps diagram the available comparative RCTs of devices represented in the literature. The maps are not comprehensive of all possible decision sets regarding implantable devices for hip fractures as the literature itself does not include RCTs for all decision sets.

Figure 7 Femoral neck decision tree/literature map

Figure 8 Pertrochanteric decision tree/literature map

NR = not reported, HA = Hydroxyapatite cement. IM Nails = intramedullary nails. PCCP = percutaneous compression plate. IMHS = intramedullary hip screw. PFN = proximal femoral nail. For further detail on types of devices, see Table 2.

Many articles reported findings on a mixed set of fracture patterns within a specific type of fracture. Some of these trials reported subgroups based on stability or displacement of the fractures, but many did not. Thus, the maps include branches that are inclusive of all fracture types. Where possible, outcomes are delineated by fracture subtypes in analyses.

Arrows with dotted shafts refer to additional decisions to be made rather than a discrete choice pair. For example, a surgeon can choose different distal locking techniques for an intramedullary nail. Without this form of identification the maps become unwieldy and difficult to use.

The decision nodes (Nodes), denoted by squares, are numbered to identify the level at which the decision is taking place, essentially between classes of devices, between types of devices within a class, and between modifications one may make to a type of device, such as using cement or changing the way a device is locked in place. The articles are organized within the evidence tables by the corresponding map node.

When measured patient outcomes were consistent across studies (e.g., mortality), quantitative summaries used forest plots. A qualitative approach was employed for all other patient outcomes. Trials at Nodes 2–4 compare specific device types, such as the general category of multiple device screws versus hook pins. Comparisons are not differentiated beyond the number of multiple device types used for fixation, i.e., two versus three femoral neck screws. Multiple devices are not differentiated by other characteristics, such as the size of the plate or the number of screws used to affix the plate to the femur. Node 1 analyses are made at the level of classes of devices. The one exception to this is Node 2 comparisons for hemi and total hip arthroplasty, which are treated as classes of devices. Results of the quantitative and qualitative analyses are compared to relevant published systematic reviews for consistency of findings. (See Appendix A for details of systematic reviews.)

As there was only one article focused exclusively on subtrochanteric fractures, we relied on the intertrochanteric literature where it included subtrochanteric fractures or intertrochanteric fractures with subtrochanteric extensions. We relied on subtrochanteric involvement as defined by the study investigators, since, as stated before, classifications systems do not by themselves provide adequate assurance of identification of subtrochanteric fracture.

## Quality and Strength of Evidence Assessment

In order to address the comprehensive model outlined in Chapter 1, we assessed the quality of each study reviewed, and employed a lower quality threshold than may be normally applied in systematic reviews when determining which articles to retain.

Two reviewers assessed the quality of all included studies. Differences of opinion were resolved by consensus adjudication of at least three reviewers. Completion of the checklist was based solely on what was reported in the articles. Studies were assigned a rating of Good, Fair, or Poor based on a 20 item checklist,22 with some slight modifications. Since allocation concealment is not fully possible for surgical procedures, we placed a heavier weight on the randomization process and evidence of changes which might impact selection bias, whether the article provided sufficient information on the patient sample, and how carefully the patient sample was defined. Therefore, articles that excluded baseline information on the patient sample by group, or articles that did not provide exclusion criteria, were given lower quality ratings. Likewise, lack of information regarding attrition due to mortality and followup losses was also weighted more heavily. With such large expected loss to mortality within the first year of a hip fracture, the total loss to followup can be substantial. Low patient numbers and loss to attrition, even if equally distributed, impact issues of power to find both Type I and Type II errors and are a major quality concern for hip fracture research as well. Articles were retained for the review if they exceeded a minimum threshold that allowed for meaningful interpretations of patient samples. Articles that did not include baseline patient characteristics by comparison group, information on randomization, exclusion criteria, or attrition, and low patient sample, were deemed not includable.

In looking across the body of evidence available, we judged both the quality and consistency of the material. We based our approach on the summarization methods advocated by the Grading of Recommendations Assessment, Development, and Evaluation (GRADE) group.23 Although the extent of heterogeneity among the studies precluded formal meta-analysis and pooling, we sought to explore the patterns across study groupings.

## Applicability

Applicability of the results of this review is affected by the representativeness of the populations recruited to the studies. The evidence tables E2 and E4 in Appendix E identify details on the patient inclusion and exclusion criteria.

The literature was generally of two kinds, articles that looked at the overall elderly hip fracture patient populations and articles that selected an elderly patient population that was healthier, more mobile, and independent prior to the hip fracture. As noted earlier, the literature is predominantly international in origin. It has been found that patients with hip fractures have similar characteristics and are comparable across most nations.90