# Appendixes

Appendix A Previously Published Systematic Reviews and Meta-analysis

Appendix B Technical Expert Panel

Appendix C Search Strings

Appendix D Abstraction Forms

Appendix E Quorum Statement and Evidence Tables

Appendix F List of Excluded Studies