# List of Excluded Studies

## Excluded from RCT Literature

1 Prevention of pulmonary embolism and deep vein thrombosis with low dose aspirin: Pulmonary Embolism Prevention (PEP) trial.[see comment]. Lancet. Apr. 15. 2000;355(9212):1295-302. Not test of device. [pmid: 10776741].
2 Fondaparinux: new preparation. No better than LMWH in preventing pulmonary embolism. Prescrire International. Feb. 2003;12(63):3-5. Not test of a device. [pmid: 12602371].
3 Aboulafia AJ, Price MM, Kennon RE, et al. A comparison of mechanical strength of the femoral neck following locked intramedullary nailing using oblique versus transverse proximal screws. Journal of Orthopaedic Trauma. Mar-Apr. 1999;13(3):160-3. Not hip fracture. [pmid: 10206246].
4 Agnelli G, Cosmi B, Radicchia S, et al. Features of thrombi and diagnostic accuracy of impedance plethysmography in symptomatic and asymptomatic deep vein thrombosis. Thrombosis & Haemostasis. Aug. 2. 1993;70(2):266-9. Not test of device. [pmid: 8236133].
5 Agnelli G, Volpato R, Radicchia S, et al. Detection of asymptomatic deep vein thrombosis by real-time B-mode ultrasonography in hip surgery patients. Thrombosis & Haemostasis. Sep. 7. 1992;68(3):257-60. Not RCT. [pmid: 1440488].
6 Ahuja S, Chatterji S. The Mennen femoral plate for fixation of periprosthetic femoral fractures following hip arthroplasty.[see comment]. Injury. Jan. 2002;33(1):47-50. Not patient population. [pmid: 11879832].
7 Alberts KA, Jaerveus J, Zyto K. Nail versus screw fixation of femoral neck fractures. A 2-year radiological and clinical prospective study. Annales Chirurgiae et Gynaecologiae. 1989;78(4):298-303. Not included device. [pmid: 2696417].
8 Alho A, Benterud JG, Ronningen H, et al. Prediction of disturbed healing in femoral neck fracture. Radiographic analysis of 149 cases. Acta Orthopaedica Scandinavica. Dec. 1992;63(6):639-44. Not RCT. [pmid: 1471513].
9 Alho A, Moen O, Husby T, et al. Slotted versus non-slotted locked intramedullary nailing for femoral shaft fractures. Archives of Orthopaedic & Trauma Surgery. 1992;111(2):91-5. Not hip fracture. [pmid: 1562431].
10 Ali M, Khan MR. Fractures of the distal femur in adults. JPMA - Journal of the Pakistan Medical Association. Aug. 1994;44(8):188-90. Not hip fracture.
11 Allain J, Roudot-Thoraval F, Delecrin J, et al. Revision total hip arthroplasty performed after fracture of a ceramic femoral head. A multicenter survivorship study. Journal of Bone & Joint Surgery - American Volume. May. 2003;85-A(5):825-30. Not hip fracture.
12 Alobaid A, Harvey EJ, Elder GM, et al. Minimally invasive dynamic hip screw: prospective randomized trial of two techniques of insertion of a standard dynamic fixation device. Journal of Orthopaedic Trauma. Apr. 2004;18(4):207-12. Not test of device. [pmid: 15087963].
13 Alonso JE, Volgas DA, Giordano V, et al. A review of the treatment of hip dislocations associated with acetabular fractures. Clinical Orthopaedics & Related Research. Aug. 2000;(377):32-43. Not hip fracture. [pmid: 10943183].
14 Andersen JC. Advances in anticoagulation therapy: the role of selective inhibitors of factor Xa and thrombin in thromboprophylaxis after major orthopedic surgery. Seminars in Thrombosis & Hemostasis. Dec. 2004;30(6):609-18. Not test of device. [pmid: 15630666].
15 Anwar IA, Battistella FD, Neiman R, et al. Femur fractures and lung complications: a prospective randomized study of reaming. Clinical Orthopaedics & Related Research. May. 2004;(422):71-6. Not hip fracture. [pmid: 15187836].
16 Ascani A, Radicchia S, Parise P, et al. Distribution and occlusiveness of thrombi in patients with surveillance detected deep vein thrombosis after hip surgery. Thrombosis & Haemostasis. Feb. 1996;75(2):239-41. Not RCT. [pmid: 8815567].
17 Au MK. Isoelastic total hip replacement: clinical evaluation of prosthetic isoelasticity. Journal of the Formosan Medical Association. Jun. 1994;93(6):497-502. Not RCT. [pmid: 7858438].
18 Audige L, Hanson B, Swiontkowski MF. Implant-related complications in the treatment of unstable intertrochanteric fractures: meta-analysis of dynamic screw-plate versus dynamic screw-intramedullary nail devices.[see comment]. International Orthopaedics. 2003;27(4):197-203. Not RCT. [pmid: 12734684].
19 Augat P, Rapp S, Claes L. A modified hip screw incorporating injected cement for the fixation of osteoporotic trochanteric fractures. Journal of Orthopaedic Trauma. May. 2002;16(5):311-6. Not patient population. [pmid: 11972073].
20 Avenell A, Gillespie WJ, Gillespie LD, et al. Vitamin D and vitamin D analogues for preventing fractures associated with involutional and post-menopausal osteoporosis.[see comment][update of Cochrane Database Syst Rev. 2001;(1):CD000227; PMID: 11279685]. Cochrane Database of Systematic Reviews. 2005;(3):CD000227. Not RCT. [pmid: 16034849].
21 Azouz EM, Karamitsos C, Reed MH, et al. Types and complications of femoral neck fractures in children. Pediatric Radiology. 1993;23(6):415-20. Not patient population. [pmid: 8255640].
22 Bach AW, Hansen ST Jr. Plates versus external fixation in severe open tibial shaft fractures. A randomized trial. Clinical Orthopaedics & Related Research. Apr. 1989;(241):89-94. Not hip fracture. [pmid: 2924483].
23 Back DL, Dalziel R, Young D, et al. Early results of primary Birmingham hip resurfacings. An independent prospective study of the first 230 hips. Journal of Bone & Joint Surgery - British Volume. Mar. 2005;87(3):324-9. Not RCT.
24 Backus CL, Heniford BT, Sing RF. Temporary vena cava filter placement for pulmonary embolism. Journal of the American Osteopathic Association. Oct. 2002;102(10):555-6. Not hip fracture. [pmid: 12401042].
25 Baele P, Beguin C, Waterloos H, et al. The Belgium BIOMED Study about transfusion for surgery. Acta Anaesthesiologica Belgica. 1998;49(4):243-303. Not test of device. [pmid: 10078310].
26 Bain GI, Zacest AC, Paterson DC, et al. Abduction strength following intramedullary nailing of the femur. Journal of Orthopaedic Trauma. Feb-Mar. 1997;11(2):93-7. Not hip fracture. [pmid: 9057142].
27 Baitner AC, Maurer SG, Hickey DG, et al. Vertical shear fractures of the femoral neck. A biomechanical study. Clinical Orthopaedics & Related Research. Oct. 1999;(367):300-5. Not patient population. [pmid: 10546628].
28 Baker A, Klimscha W, Eisenach JC, et al. Intrathecal clonidine for postoperative analgesia in elderly patients: the influence of baricity on hemodynamic and analgesic effects. Anesthesia & Analgesia. Jul. 2004;99(1):128-34. Not test of device. [pmid: 15281518].
29 Banan H, Al-Sabti A, Jimulia T, et al. The treatment of unstable, extracapsular hip fractures with the AO/ASIF proximal femoral nail (PFN)--our first 60 cases. Injury. Jun. 2002;33(5):401-5. Not RCT. [pmid: 12095719].
30 Bannister GC, Gibson AG, Ackroyd CE, et al. The fixation and prognosis of trochanteric fractures. A randomized prospective controlled trial. Clinical Orthopaedics & Related Research. May. 1990;(254):242-6. Not included device. [pmid: 2182255].
31 Bargar WL, Bauer A, Borner M. Primary and revision total hip replacement using the Robodoc system. Clinical Orthopaedics & Related Research. Sep. 1998;(354):82-91. Not hip fracture. [pmid: 9755767].
32 Bar-On E, Sagiv S, Porat S. External fixation or flexible intramedullary nailing for femoral shaft fractures in children. A prospective, randomised study.[see comment][erratum appears in J Bone Joint Surg Br 1998 Jul;80(4):749]. Journal of Bone & Joint Surgery - British Volume. Nov. 1997;79(6):975-8. Not hip fracture.
33 Baron JA, Barrett J, Katz JN, et al. Total hip arthroplasty: use and select complications in the US Medicare population. American Journal of Public Health. Jan. 1996;86(1):70-2. Not hip fracture. [pmid: 8561246].
34 Barquet A, Francescoli L, Rienzi D, et al. Intertrochanteric-subtrochanteric fractures: treatment with the long Gamma nail. Journal of Orthopaedic Trauma. Jun-Jul. 2000;14(5):324-8. Not patient population. [pmid: 10926238].
35 Barrios C, Brostrom LA, Stark A, et al. Healing complications after internal fixation of trochanteric hip fractures: the prognostic value of osteoporosis. Journal of Orthopaedic Trauma. 1993;7(5):438-42. Not included device. [pmid: 8229380].
36 Barrios C, Walheim G, Brostrom LA, et al. Walking ability after internal fixation of trochanteric hip fractures with Ender nails or sliding screw plate. A comparative study of gait. Clinical Orthopaedics & Related Research. Sep. 1993;(294):187-92. Not included device. [pmid: 8358913].
37 Barsotti J, Gruel Y, Rosset P, et al. Comparative double-blind study of two dosage regimens of low-molecular weight heparin in elderly patients with a fracture of the neck of the femur. Journal of Orthopaedic Trauma. 1990;4(4):371-5. Not test of device. [pmid: 2176235].
38 Bartonicek I, Dousa P. Prospective randomized controlled trial of an intramedullary nail versus dynamic screw and plate of intertrochanteric fractures of the femur.[comment]. Journal of Orthopaedic Trauma. May. 2002;16(5):363-4. author reply 4. Other exclusion - comment to RCT. [pmid: 11972084].
39 Basumallick MN, Bandopadhyay A. Effect of dynamization in open interlocking nailing of femoral fractures. A prospective randomized comparative study of 50 cases with a 2-year follow-up. Acta Orthopaedica Belgica. Feb. 2002;68(1):42-8. Not hip fracture. [pmid: 11915458].
40 Baumgaertel F, Dahlen C, Stiletto R, et al. Technique of using the AO-femoral distractor for femoral intramedullary nailing. Journal of Orthopaedic Trauma. Aug. 1994;8(4):315-21. Not hip fracture. [pmid: 7965293].
41 Bell RS, Schatzker J, Fornasier VL, et al. A study of implant failure in the Wagner resurfacing arthroplasty. Journal of Bone & Joint Surgery - American Volume. Oct. 1985;67(8):1165-75. Not RCT.
42 Berglund-Roden M, Swierstra BA, Wingstrand H, et al. Prospective comparison of hip fracture treatment. 856 cases followed for 4 months in The Netherlands and Sweden. Acta Orthopaedica Scandinavica. Jun. 1994;65(3):287-94. Not RCT. [pmid: 8042480].
43 Bhandari M, Devereaux PJ, Swiontkowski MF, et al. Internal fixation compared with arthroplasty for displaced fractures of the femoral neck. A meta-analysis. Journal of Bone & Joint Surgery - American Volume. Sep. 2003;85-A(9):1673-81. Not RCT.
44 Bhandari M, Devereaux PJ, Tornetta P 3rd, et al. Operative management of displaced femoral neck fractures in elderly patients. An international survey. Journal of Bone & Joint Surgery - American Volume. Sep. 2005;87(9):2122-30. Not RCT.
45 Bhandari M, Guyatt GH, Khera V, et al. Operative management of lower extremity fractures in patients with head injuries.[see comment]. Clinical Orthopaedics & Related Research. Feb. 2003;(407):187-98. Not hip fracture. [pmid: 12567146].
46 Bhandari M, Guyatt GH, Tong D, et al. Reamed versus nonreamed intramedullary nailing of lower extremity long bone fractures: a systematic overview and meta-analysis.[see comment]. Journal of Orthopaedic Trauma. Jan. 2000;14(1):2-9. Not hip fracture. [pmid: 10630795].
47 Bhandari M, Tornetta Pr, Ellis T, et al. Hierarchy of evidence: differences in results between non-randomized studies and randomized trials in patients with femoral neck fractures. Archives of Orthopaedic & Trauma Surgery. Jan. 2004;124(1):10-6. Not RCT. [pmid: 14576955].
48 Bhandari M, Zlowodzki M, Tornetta P 3rd, et al. Intramedullary nailing following external fixation in femoral and tibial shaft fractures. Journal of Orthopaedic Trauma. Feb. 2005;19(2):140-4. Not hip fracture. [pmid: 15677932].
49 Bienkowski P, Reindl R, Berry GK, et al. A new intramedullary nail device for the treatment of intertrochanteric hip fractures: Perioperative experience. Journal of Trauma-Injury Infection & Critical Care. Dec. 2006;61(6):1458-62. Not RCT.
50 Blair B, Koval KJ, Kummer F, et al. Basicervical fractures of the proximal femur. A biomechanical study of 3 internal fixation techniques. Clinical Orthopaedics & Related Research. Sep. 1994;(306):256-63. Other exclusion - cadaver. [pmid: 8070205].
51 Bleakney R, Maffulli N. Ultrasound changes to intramuscular architecture of the quadriceps following intramedullary nailing. Journal of Sports Medicine & Physical Fitness. Mar. 2002;42(1):120-5. Not hip fracture. [pmid: 11832886].
52 Blomfeldt R, Tornkvist H, Ponzer S, et al. Displaced femoral neck fracture: comparison of primary total hip replacement with secondary replacement after failed internal fixation: a 2-year follow-up of 84 patients. Acta Orthopaedica. Aug. 2006;77(4):638-43. Not RCT. [pmid: 16929442].
53 Blumberg KD, Foster WC, Blumberg JF, et al. A comparison of the Brooker-Wills and Russell-Taylor nails for treatment of patients who have fractures of the femoral shaft. Journal of Bone & Joint Surgery - American Volume. Aug. 1990;72(7):1019-24. Not hip fracture.
54 Bodoky A, Neff U, Heberer M, et al. Antibiotic prophylaxis with two doses of cephalosporin in patients managed with internal fixation for a fracture of the hip. Journal of Bone & Joint Surgery - American Volume. Jan. 1993;75(1):61-5. Not test of device.
55 Bone LB, Johnson KD, Weigelt J, et al. Early versus delayed stabilization of femoral fractures. A prospective randomized study.[see comment]. Journal of Bone & Joint Surgery - American Volume. Mar. 1989;71(3):336-40. Not test of device.
56 Bone LB, Johnson KD, Weigelt J, et al. Early versus delayed stabilization of femoral fractures: a prospective randomized study. 1989. Clinical Orthopaedics & Related Research. May. 2004;(422):11-6. Not test of device. [pmid: 15187827].
57 Booth KC, Donaldson TK, Dai QG. Femoral neck fracture fixation: a biomechanical study of two cannulated screw placement techniques.[see comment][erratum appears in Orthopedics 1999 May;22(5):477]. Orthopedics. Nov. 1998;21(11):1173-6. Not patient population. [pmid: 9845448].
58 Boriani S, Bettelli G, Zmerly H, et al. Results of the multicentric Italian experience on the Gamma nail: a report on 648 cases.[erratum appears in Orthopedics 1992 May;15(5):545]. Orthopedics. Dec. 1991;14(12):1307-14. Not RCT. [pmid: 1784547].
59 Boriani S, De Iure F, Bettelli G, et al. The results of a multicenter Italian study on the use of the Gamma nail for the treatment of pertrochanteric and subtrochanteric fractures: a review of 1181 cases. Chirurgia Degli Organi di Movimento. Apr-Jun. 1994;79(2):193-203. Not RCT. [pmid: 7956521].
60 Boriani S, De lure F, Campanacci L, et al. A technical report reviewing the use of the 11-mm Gamma nail: interoperative femur fracture incidence. Orthopedics. Jul. 1996;19(7):597-600. Not RCT. [pmid: 8823818].
61 Borrelli J Jr, Ricci WM, Anglen JO, et al. Muscle strength recovery and its effects on outcome after open reduction and internal fixation of acetabular fractures. Journal of Orthopaedic Trauma. Jul. 2006;20(6):388-95. Not RCT. [pmid: 16825963].
62 Bostrom MP, Lyden JP, Ernberg JJ, et al. A biomechanical evaluation of the long stem intramedullary hip screw. Journal of Orthopaedic Trauma. Feb. 1995;9(1):45-52. Not patient population. [pmid: 7714653].
63 Bottle A, Aylin P. Mortality associated with delay in operation after hip fracture: observational study.[see comment]. BMJ. Apr. 22. 2006;332(7547):947-51. Not RCT. [pmid: 16554334].
64 Brandt E, Verdonschot N, van Vugt A, et al. Biomechanical analysis of the percutaneous compression plate and sliding hip screw in intracapsular hip fractures: experimental assessment using synthetic and cadaver bones. Injury. Oct. 2006;37(10):979-83. Not RCT. [pmid: 16934259].
65 Braten M, Tveit K, Junk S, et al. The role of fluoroscopy in avoiding rotational deformity of treated femoral shaft fractures: an anatomical and clinical study. Injury. Jun. 2000;31(5):311-5. Not hip fracture. [pmid: 10775683].
66 Bray TJ, Smith-Hoefer E, Hooper A, et al. The displaced femoral neck fracture. Internal fixation versus bipolar endoprosthesis. Results of a prospective, randomized comparison. Clinical Orthopaedics & Related Research. May. 1988;(230):127-40. Not RCT - assignment according to MD philosophy. [pmid: 3365885].
67 Brinker MR, Reuben JD, Mull JR, et al. Comparison of general and epidural anesthesia in patients undergoing primary unilateral THR. Orthopedics. Feb. 1997;20(2):109-15. Not test of device. [pmid: 9048387].
68 Brogen J, Kelsberg G, Safranek S, et al. Clinical inquiries. Does anticoagulation prevent thrombosis for persons with fractures distal to the hip?. Journal of Family Practice. Apr. 2005;54(4):376-7. Not hip fracture. [pmid: 15833234].
69 Broos P, Reynders P. The unreamed AO femoral intramedullary nail, advantages and disadvantages of a new modular interlocking system. A prospective study of 67 cases. Acta Orthopaedica Belgica. Sep. 1998;64(3):284-90. Not RCT. [pmid: 9828474].
70 Broos P, Vanderspeeten K. Our first experiences with the Unreamed Femoral Nail (UFN). Acta Chirurgica Belgica. Jan-Feb. 1997;97(1):27-32. Not RCT. [pmid: 9079141].
71 Broos PLO, Reynders P. The use of the unreamed AO femoral intramedullary nail with spiral blade in nonpathologic fractures of the femur: experiences with eighty consecutive cases. Journal of Orthopaedic Trauma. Mar. 2002;16(3):150-4. Not RCT. [pmid: 11880776].
72 Brostrom LA, Barrios C, Kronberg M, et al. Clinical features and walking ability in the early postoperative period after treatment of trochanteric hip fractures. Results with special reference to fracture type and surgical treatment. Annales Chirurgiae et Gynaecologiae. 1992;81(1):66-71. Not included device. [pmid: 1622057].
73 Brown AG, Visram AR, Jones RD, et al. Preoperative and postoperative oxygen saturation in the elderly following spinal or general anaesthesia--an audit of current practice. Anaesthesia & Intensive Care. Apr. 1994;22(2):150-4. Not test of device. [pmid: 8210017].
74 Brumback RJ, Wells JD, Lakatos R, et al. Heterotopic ossification about the hip after intramedullary nailing for fractures of the femur.[see comment]. Journal of Bone & Joint Surgery - American Volume. Aug. 1990;72(7):1067-73. Not hip fracture.
75 Buciuto R, Hammer R. RAB-plate versus sliding hip screw for unstable trochanteric hip fractures: stability of the fixation and modes of failure--radiographic analysis of 218 fractures. Journal of Trauma-Injury Infection & Critical Care. Mar. 2001;50(3):545-50. Not RCT.
76 Buciuto R, Hammer R, Herder A. Spontaneous subcapital femoral neck fracture after healed trochanteric fracture. Clinical Orthopaedics & Related Research. Sep. 1997;(342):156-63. Not RCT - comparison group not random. [pmid: 9308538].
77 Buciuto R, Uhlin B, Hammerby S, et al. RAB-plate vs Richards CHS plate for unstable trochanteric hip fractures. A randomized study of 233 patients with 1-year follow-up.[see comment]. Acta Orthopaedica Scandinavica. Feb. 1998;69(1):25-8. Not included device. [pmid: 9524512].
78 Buggy DJ, Power CK, Meeke R, et al. Prevention of spinal anaesthesia-induced hypotension in the elderly: i.m. methoxamine or combined hetastarch and crystalloid. British Journal of Anaesthesia. Feb. 1998;80(2):199-203. Not test of device. [pmid: 9602585].
79 Burgos E, Gomez-Arnau JI, Diez R, et al. Predictive value of six risk scores for outcome after surgical repair of hip fracture in elderly patients. Acta Anaesthesiologica Scandinavica. Jan. 2008;52(1):125-31. Not RCT. [pmid: 17996004].
80 Burns RB, Moskowitz MA, Ash A, et al. Variations in the performance of hip fracture procedures. Medical Care. Mar. 1997;35(3):196-203. Not RCT. [pmid: 9071253].
81 Butt MS, Krikler SJ, Ali MS. Displaced fractures of the distal femur in elderly patients. Operative versus non-operative treatment. Journal of Bone & Joint Surgery - British Volume. Jan. 1996;78(1):110-4. Not hip fracture.
82 Calder S. The compares a unipolar with a bipolar prosthesis of similar stem design.[comment]. Clinical Orthopaedics & Related Research. Feb. 1999;(359):259. Other exclusion - comment to RCT. [pmid: 10078152].
83 Calder SJ, Anderson GH, Harper WM, et al. A subjective health indicator for follow-up. A randomised trial after treatment of displaced intracapsular hip fractures. Journal of Bone & Joint Surgery - British Volume. May. 1995;77(3):494-6. Other exclusion - early report to validate QoL measure/method.
84 Calder SJ, Barnes MR, Harper WM. Reduction of temperatures generated by the triple reamer within the femoral head. Injury. Apr. 1995;26(3):183-5. Not test of device. [pmid: 7744475].
85 Cameron CD, Meek RN, Blachut PA, et al. Intramedullary nailing of the femoral shaft: a prospective, randomized study. Journal of Orthopaedic Trauma. 1992;6(4):448-51. Not hip fracture. [pmid: 1494099].
86 Cameron HU. Six-year results with a microporous-coated metal hip prosthesis. Clinical Orthopaedics & Related Research. Jul. 1986;(208):81-3. Not RCT. [pmid: 3522027].
87 Canadian Orthopaedic Trauma S. Nonunion following intramedullary nailing of the femur with and without reaming. Results of a multicenter randomized clinical trial. Journal of Bone & Joint Surgery - American Volume. Nov. 2003;85-A(11):2093-6. Not hip fracture.
88 Canadian Orthopaedic Trauma S. Reamed versus unreamed intramedullary nailing of the femur: comparison of the rate of ARDS in multiple injured patients.[see comment]. Journal of Orthopaedic Trauma. Jul. 2006;20(6):384-7. Not hip fracture. [pmid: 16825962].
89 Capello WN, D'Antonio JA, Feinberg JR, et al. Hydroxyapatite-coated total hip femoral components in patients less than fifty years old. Clinical and radiographic results after five to eight years of follow- up. Journal of Bone & Joint Surgery - American Volume. Jul. 1997;79(7):1023-9. Not patient population.
90 Carmeli E, Sheklow SL, Coleman R. A comparative study of organized class-based exercise programs versus individual home-based exercise programs for elderly patients following hip surgery. Disability & Rehabilitation. Aug. 30. 2006;28(16):997-1005. Not test of device. [pmid: 16882639].
91 Carragee EJ, Vittum D, Truong TP, et al. Pain control and cultural norms and expectations after closed femoral shaft fractures. American Journal of Orthopedics. Feb. 1999;28(2):97-102. Not hip fracture. [pmid: 10067712].
92 Ceffa R, Bombelli M, Boero S, et al. Extensimetric monitoring of healing in the treatment with the Ilizarov apparatus. A multicenter clinical trial. Bulletin of the Hospital for Joint Diseases. 1997;56(1):41-5. Not test of device.
93 Chakravarthy J, Mangat K, Qureshi A, et al. Postoperative radiographs following hip fracture surgery. Do they influence patient management?. International Journal of Clinical Practice. Mar. 2007;61(3):421-4. Not RCT. [pmid: 17313609].
94 Chang WS, Zuckerman JD, Kummer FJ, et al. Biomechanical evaluation of anatomic reduction versus medial displacement osteotomy in unstable intertrochanteric fractures. Clinical Orthopaedics & Related Research. Dec. 1987;(225):141-6. Not patient population. [pmid: 3677508].
95 Chapuy MC, Pamphile R, Paris E, et al. Combined calcium and vitamin D3 supplementation in elderly women: confirmation of reversal of secondary hyperparathyroidism and hip fracture risk: the Decalyos II study. Osteoporosis International. Mar. 2002;13(3):257-64. Not test of device. [pmid: 11991447].
96 Cheng JWM. Fondaparinux: a new antithrombotic agent. Clinical Therapeutics. Nov. 2002;24(11):1757-69. discussion 19. Not test of device. [pmid: 12501872].
97 Chevalley F, Gamba D. Gamma nailing of pertrochanteric and subtrochanteric fractures: clinical results of a series of 63 consecutive cases. Journal of Orthopaedic Trauma. Aug. 1997;11(6):412-5. Not RCT. [pmid: 9314147].
98 Chilov MN, Cameron ID, March LM, et al. Evidence-based guidelines for fixing broken hips: an update.[see comment]. Medical Journal of Australia. Nov. 3. 2003;179(9):489-93. Not RCT. [pmid: 14583081].
99 Chinoy MA, Parker MJ. Fixed nail plates versus sliding hip systems for the treatment of trochanteric femoral fractures: a meta analysis of 14 studies. Injury. Apr. 1999;30(3):157-63. Not RCT. [pmid: 10476259].
100 Chiu KY, Lau SK, Fung B, et al. Plastic adhesive drapes and wound infection after hip fracture surgery. Australian & New Zealand Journal of Surgery. Oct. 1993;63(10):798-801. Not a test of device or US device. [pmid: 8274123].
101 Choi IH, Chung CY, Cho TJ, et al. Correction of genu recurvatum by the Ilizarov method. Journal of Bone & Joint Surgery - British Volume. Sep. 1999;81(5):769-74. Not hip fracture.
102 Chong KW, Wong MK, Rikhraj IS, et al. The use of computer navigation in performing minimally invasive surgery for intertrochanteric hip fractures--The experience in Singapore.[see comment]. Injury. Aug. 2006;37(8):755-62. Not RCT. [pmid: 16765957].
103 Choueka J, Koval KJ, Kummer FJ, et al. Biomechanical comparison of the sliding hip screw and the dome plunger. Effects of material and fixation design. Journal of Bone & Joint Surgery - British Volume. Mar. 1995;77(2):277-83. Not patient population.
104 Christie J, Burnett R, Potts HR, et al. Echocardiography of transatrial embolism during cemented and uncemented hemiarthroplasty of the hip. Journal of Bone & Joint Surgery - British Volume. May. 1994;76(3):409-12. Other exclusion.
105 Christie J, Howie CR, Armour PC. Fixation of displaced subcapital femoral fractures. Compression screw fixation versus double divergent pins. Journal of Bone & Joint Surgery - British Volume. Mar. 1988;70(2):199-201. Not included device.
106 Christie J, Robinson CM, Singer B, et al. Medullary lavage reduces embolic phenomena and cardiopulmonary changes during cemented hemiarthroplasty. Journal of Bone & Joint Surgery - British Volume. May. 1995;77(3):456-9. Not test of device.
107 Christodoulou A, Terzidis I, Ploumis A, et al. Supracondylar femoral fractures in elderly patients treated with the dynamic condylar screw and the retrograde intramedullary nail: a comparative study of the two methods. Archives of Orthopaedic & Trauma Surgery. Mar. 2005;125(2):73-9. Not hip fracture. [pmid: 15611863].
108 Cirillo DJ, Wallace RB, Wu L, et al. Effect of hormone therapy on risk of hip and knee joint replacement in the Women's Health Initiative. Arthritis & Rheumatism. Oct. 2006;54(10):3194-204. Not hip fracture. [pmid: 17009251].
109 Clark DI, Ahmed AB, Baxendale BR, et al. Cardiac output during hemiarthroplasty of the hip. A prospective, controlled trial of cemented and uncemented prostheses.[see comment]. Journal of Bone & Joint Surgery - British Volume. Apr. 2001;83(3):414-8. Other exclusion.
110 Clark DW, Ribbans WJ. Treatment of unstable intertrochanteric fractures of the femur: a prospective trial comparing anatomical reduction and valgus osteotomy. Injury. Mar. 1990;21(2):84-8. Not test of device. [pmid: 2190935].
111 Clatworthy MG, Clark DI, Gray DH, et al. Reamed versus unreamed femoral nails. A randomised, prospective trial.[see comment]. Journal of Bone & Joint Surgery - British Volume. May. 1998;80(3):485-9. Not hip fracture.
112 Clinkscales CM, Peterson HA. Isolated closed diaphyseal fractures of the femur in children: comparison of effectiveness and cost of several treatment methods. Orthopedics. Dec. 1997;20(12):1131-6. Not hip fracture. [pmid: 9415908].
113 Coad NR. Post-operative analgesia following femoral-neck surgery--a comparison between 3 in 1 femoral nerve block and lateral cutaneous nerve block. European Journal of Anaesthesiology. Jul. 1991;8(4):287-90. Not a test of device or US device. [pmid: 1874226].
114 Cohen AT, Skinner JA, Warwick D, et al. The use of graduated compression stockings in association with fondaparinux in surgery of the hip. A multicentre, multinational, randomised, open-label, parallel-group comparative study. Journal of Bone & Joint Surgery - British Volume. Jul. 2007;89(7):887-92. Not test of device.
115 Cohen AT, Skinner JA, Warwick D, et al. The use of graduated compression stockings in association with fondaparinux in surgery of the hip. A multicentre, multinational, randomised, open-label, parallel-group comparative study.[see comment]. Journal of Bone & Joint Surgery - British Volume. Jul. 2007;89(7):887-92. Not test of device.
116 Coles RE, Clements FM, Lardenoye JW, et al. Transesophageal echocardiography in quantification of emboli during femoral nailing: reamed versus unreamed techniques. Journal of the Southern Orthopaedic Association. 2000;9(2):98-104. Not patient population. [pmid: 10901647].
117 Colwell C, Mouret P. Ximelagatran for the prevention of venous thromboembolism following elective hip or knee replacement surgery. Seminars in Vascular Medicine. Aug. 2005;5(3):266-75. Not hip fracture. [pmid: 16123914].
118 Colwell CW Jr. Rationale for thromboprophylaxis in lower joint arthroplasty. American Journal of Orthopedics. Sep. 2007;36(9 Suppl):11-3. Not RCT. [pmid: 17948162].
119 Craig NJ, Sivaji C, Maffulli N. Subtrochanteric fractures. A review of treatment options. Bulletin of the Hospital for Joint Diseases. 2001;60(1):35-46. Not RCT.
120 Cserhati P, Fekete K, Berglund-Roden M, et al. Hip fractures in Hungary and Sweden - differences in treatment and rehabilitation. International Orthopaedics. 2002;26(4):222-8. Not RCT. [pmid: 12185524].
121 Cuenca J, Garcia-Erce JA, Martinez AA, et al. Role of parenteral iron in the management of anaemia in the elderly patient undergoing displaced subcapital hip fracture repair: preliminary data. Archives of Orthopaedic & Trauma Surgery. Jun. 2005;125(5):342-7. Not RCT. [pmid: 15789233].
122 Curtis JF, Killian JT, Alonso JE. Improved treatment of femoral shaft fractures in children utilizing the pontoon spica cast: a long-term follow-up. Journal of Pediatric Orthopedics. Jan-Feb. 1995;15(1):36-40. Not hip fracture. [pmid: 7883925].
123 Dalen N, Jacobsson B. Factors influencing the incidence of reoperation after femoral neck fractures. International Orthopaedics. 1985;9(4):235-7. Other exclusions - comparison group not random. [pmid: 4093224].
124 Dalen N, Jacobsson B, Eriksson PA. A comparison of nail-plate fixation and Ender's nailing in pertrochanteric fractures. Journal of Trauma-Injury Infection & Critical Care. Mar. 1988;28(3):405-6. Not included device.
125 Danziger MB, Caucci D, Zecher SB, et al. Treatment of intercondylar and supracondylar distal femur fractures using the GSH supracondylar nail. American Journal of Orthopedics. Sep. 1995;24(9):684-90. Not hip fracture. [pmid: 8548263].
126 Darling JR, Murray JM, Hainsworth AM, et al. The effect of isoflurane or spinal anesthesia on indocyanine green disappearance rate in the elderly. Anesthesia & Analgesia. Apr. 1994;78(4):706-9. Not test of device. [pmid: 8135390].
127 David SM, Harrow ME, Peindl RD, et al. Comparative biomechanical analysis of supracondylar femur fracture fixation: locked intramedullary nail versus 95- degree angled plate. Journal of Orthopaedic Trauma. Jul. 1997;11(5):344-50. Not hip fracture. [pmid: 9294798].
128 Davies MS, Flannery MC, McCollum CN. Calcium alginate as haemostatic swabs in hip fracture surgery.[see comment]. Journal of the Royal College of Surgeons of Edinburgh. Feb. 1997;42(1):31-2. Not test of device. [pmid: 9046141].
129 Davis FM, Woolner DF, Frampton C, et al. Prospective, multi-centre trial of mortality following general or spinal anaesthesia for hip fracture surgery in the elderly. British Journal of Anaesthesia. Sep. 1987;59(9):1080-8. Not test of device. [pmid: 3311100].
130 Davis TR, Sher JL, Checketts RG, et al. Intertrochanteric fractures of the femur: a prospective study comparing the use of the Kuntscher-Y nail and a sliding hip screw. Injury. Nov. 1988;19(6):421-6. Not included device. [pmid: 3267650].
131 Day GA, Swanson C, Yelland C, et al. Surgical outcomes of a randomized prospective trial involving patients with a proximal femoral fracture.[see comment]. ANZ Journal of Surgery. Jan. 2001;71(1):11-4. Not RCT. [pmid: 11167590].
132 de Ridder VA, de Lange S. Use of an intramedullary hip-screw compared with a compression hip-screw with a plate for intertrochanteric femoral fractures. A prospective, randomized study of one hundred patients.[comment]. Journal of Bone & Joint Surgery - American Volume. Oct. 1999;81(10):1502-3. Not hip fracture.
133 de Ridder VA, de Lange S, Koomen AR, et al. Partridge osteosynthesis: a prospective clinical study on the use of nylon cerclage bands and plates in the treatment of periprosthetic femoral shaft fractures. Journal of Orthopaedic Trauma. Jan. 2001;15(1):61-5. Not hip fracture. [pmid: 11147690].
134 de Roeck N. A prospective, randomised trial of internal fixation versus arthroplasty for displaced fractures of the neck of the femur.[comment]. Journal of Bone & Joint Surgery - British Volume. Apr. 2003;85(3):464-5. author reply 5. Not RCT.
135 Degreif J, Muller LP, Runkel M, et al. Long-term results after operative treatment of femoral neck fractures with ceramic head prostheses. Orthopedics. Feb. 2001;24(2):129-33. Not RCT. [pmid: 11284595].
136 Delmas PD, Licata AA, Reginster JY, et al. Fracture risk reduction during treatment with teriparatide is independent of pretreatment bone turnover. Bone. Aug. 2006;39(2):237-43. Not hip fracture. [pmid: 16563890].
137 Deneka DA, Simonian PT, Stankewich CJ, et al. Biomechanical comparison of internal fixation techniques for the treatment of unstable basicervical femoral neck fractures. Journal of Orthopaedic Trauma. Jul. 1997;11(5):337-43. Not patient population. [pmid: 9294797].
138 Deshmukh RG, Lou KK, Neo CB, et al. A technique to obtain correct rotational alignment during closed locked intramedullary nailing of the femur. Injury. Apr. 1998;29(3):207-10. Not hip fracture. [pmid: 9709422].
139 Desjardins AL, Roy A, Paiement G, et al. Unstable intertrochanteric fracture of the femur. A prospective randomised study comparing anatomical reduction and medial displacement osteotomy. Journal of Bone & Joint Surgery - British Volume. May. 1993;75(3):445-7. Not test of device.
140 Devgan A, Sangwan SS. External fixator in the management of trochanteric fractures in high risk geriatric patients--a friend to the elderly. Indian Journal of Medical Sciences. Aug. 2002;56(8):385-90. Not included device. [pmid: 12645164].
141 Dhakal AP, Awais SM. Management of femur shaft fracture with close locked intramedullary nailing: comparison of Variwall and predrilled Kuntscher nail. Nepal Medical College Journal: NMCJ. Dec. 2003;5(2):73-8. Not hip fracture. [pmid: 15024770].
142 DiCicco JD 3rd, Jenkins M, Ostrum RF. Retrograde nailing for subtrochanteric femur fractures. American Journal of Orthopedics. Sep. 2000;29(9 Suppl):4-8. Not RCT. [pmid: 11011773].
143 Dobesh PP. Novel concepts: emerging data and the role of extended prophylaxis following hip fracture surgery. American Journal of Health-System Pharmacy. Nov. 15. 2003;60(22 Suppl 7):S15-9. Not test of device. [pmid: 14650862].
144 Dobrydnjov I, Axelsson K, Samarutel J, et al. Postoperative pain relief following intrathecal bupivacaine combined with intrathecal or oral clonidine. Acta Anaesthesiologica Scandinavica. Aug. 2002;46(7):806-14. Not test of device. [pmid: 12139535].
145 Dobrydnjov I, Samarutel J. Enhancement of intrathecal lidocaine by addition of local and systemic clonidine. Acta Anaesthesiologica Scandinavica. May. 1999;43(5):556-62. Not test of device. [pmid: 10342005].
146 Domb BG, Sponseller PD, Ain M, et al. Comparison of dynamic versus static external fixation for pediatric femur fractures. Journal of Pediatric Orthopedics. Jul-Aug. 2002;22(4):428-30. Not hip fracture. [pmid: 12131435].
147 Donati D, Capanna R, Campanacci D, et al. The use of massive bone allografts for intercalary reconstruction and arthrodeses after tumor resection. A multicentric European study. Chirurgia Degli Organi di Movimento. Apr-Jun. 1993;78(2):81-94. Not hip fracture. [pmid: 8344079].
148 Dong QR, Dong TH, Tang TS. Hook-pin and compression screw in the treatment of femoral neck fractures. Clinical trial and biomechanical study. Chinese Medical Journal. Jan. 1993;106(1):53-6. Not RCT. [pmid: 8504685].
149 Dorr LD, Glousman R, Hoy AL, et al. Treatment of femoral neck fractures with total hip replacement versus cemented and noncemented hemiarthroplasty. Journal of Arthroplasty. 1986;1(1):21-8. Not RCT - partial randomization. [pmid: 3559574].
150 Dujardin FH, Benez C, Polle G, et al. Prospective randomized comparison between a dynamic hip screw and a mini-invasive static nail in fractures of the trochanteric area: preliminary results. Journal of Orthopaedic Trauma. Aug. 2001;15(6):401-6. Not included device. [pmid: 11514766].
151 Eikelboom JW, Ginsberg JS. Preventing thromboembolic complications in older orthopaedic surgery patients: interventions and outcomes. Drugs & Aging. Oct. 1999;15(4):297-306. Not RCT. [pmid: 10582776].
152 Elder GM, Harvey EJ, Vaidya R, et al. The effectiveness of orthopaedic trauma theatres in decreasing morbidity and mortality: a study of 701 displaced subcapital hip fractures in two trauma centres. Injury. Sep. 2005;36(9):1060-6. Not RCT. [pmid: 16098334].
153 Elder S, Frankenburg E, Goulet J, et al. Biomechanical evaluation of calcium phosphate cement-augmented fixation of unstable intertrochanteric fractures. Journal of Orthopaedic Trauma. Aug. 2000;14(6):386-93. Not RCT. [pmid: 11001411].
154 Elmerson S, Andersson GB, Irstam L, et al. Internal fixation of femoral neck fracture. No difference between the Rydell four-flanged nail and Gouffon's pins. Acta Orthopaedica Scandinavica. Aug. 1988;59(4):372-6. Not included device. [pmid: 3421071].
155 Elmstedt E, Lindholm TS, Nilsson OS, et al. Effect of ibuprofen on heterotopic ossification after hip replacement. Acta Orthopaedica Scandinavica. Feb. 1985;56(1):25-7. Not test of device. [pmid: 3920862].
156 Eneroth M, Olsson U-B, Thorngren K-G. Nutritional supplementation decreases hip fracture-related complications.[see comment]. Clinical Orthopaedics & Related Research. Oct. 2006;451:212-7. Not test of device. [pmid: 16770284].
157 Eriksson BI. Improvements in the prevention of postoperative venous thromboembolism in hip fracture patients. Orthopedics. Aug. 2003;26(8 Suppl):s851-8. Not test of device. [pmid: 12934740].
158 Esser MP, Kassab JY, Jones DH. Trochanteric fractures of the femur. A randomised prospective trial comparing the Jewett nail-plate with the dynamic hip screw. Journal of Bone & Joint Surgery - British Volume. Aug. 1986;68(4):557-60. Not included device.
159 Etchebehere EC, Caron M, Pereira JA, et al. Activation of the growth plates on three-phase bone scintigraphy: the explanation for the overgrowth of fractured femurs. European Journal of Nuclear Medicine. Jan. 2001;28(1):72-80. Not hip fracture. [pmid: 11202455].
160 Feng M-l, Shen H-l, Hu H-j, et al. Analysis of prosthetic replacement in treatment of femoral neck fracture on the hemiplegia side in the elderly. Chinese Journal of Traumatology. Jun. 2004;7(3):138-42. Not RCT. [pmid: 15294109].
161 Field RE, Rushton N. Five-year clinical, radiological and postmortem results of the Cambridge Cup in patients with displaced fractures of the neck of the femur. Journal of Bone & Joint Surgery - British Volume. Oct. 2005;87(10):1344-51. Not a test of device or US device.
162 Fink B, Grossmann A. Modified transfemoral approach to revision arthroplasty with uncemented modular revision stems. Operative Orthopadie und Traumatologie. Mar. 2007;19(1):32-55. Not hip fracture. [pmid: 17345026].
163 Flynn JM, Hresko T, Reynolds RA, et al. Titanium elastic nails for pediatric femur fractures: a multicenter study of early results with analysis of complications. Journal of Pediatric Orthopedics. Jan-Feb. 2001;21(1):4-8. Not patient population. [pmid: 11176345].
164 Forster MC, Aster AS, Ahmed S. Reaming during anterograde femoral nailing: is it worth it?. Injury. Mar. 2005;36(3):445-9. Not RCT. [pmid: 15710164].
165 Fredman B, Zohar E, Golan E, et al. Diclofenac does not decrease renal blood flow or glomerular filtration in elderly patients undergoing orthopedic surgery. Anesthesia & Analgesia. Jan. 1999;88(1):149-54. Not test of device. [pmid: 9895083].
166 Fredman B, Zohar E, Tarabykin A, et al. Continuous intravenous diclofenac does not induce opioid-sparing or improve analgesia in geriatric patients undergoing major orthopedic surgery. Journal of Clinical Anesthesia. Nov. 2000;12(7):531-6. Not test of device. [pmid: 11137414].
167 Friedl W. Relevance of osteotomy and implant characteristics in inter- and subtrochanteric osteotomies. Experimental examination under alternating and static load after stabilisation with different devices including gamma nail osteosynthesis. Archives of Orthopaedic & Trauma Surgery. 1993;113(1):5-11. Not patient population. [pmid: 8117512].
168 Fritz T, Weiss C, Krieglstein C, et al. The classic nail in the therapy of trochanteric fractures.A prospective, controlled study. Archives of Orthopaedic & Trauma Surgery. 1999;119(5–6):308-14. Not RCT. [pmid: 10447629].
169 Fugere F, Owen H, Ilsley AH, et al. Changes in oxygen saturation in the 72 hours after hip surgery: the effect of oxygen therapy. Anaesthesia & Intensive Care. Dec. 1994;22(6):724-8. Not test of device. [pmid: 7892983].
170 Gammer W, Bengtson A, Heideman M. Inhibition of complement activation by high-dose corticosteroids in total hip arthroplasty. Clinical Orthopaedics & Related Research. Nov. 1988;(236):205-9. Not test of device. [pmid: 3263243].
171 Gargan MF, Gundle R, Simpson AH. How effective are osteotomies for unstable intertrochanteric fractures?. Journal of Bone & Joint Surgery - British Volume. Sep. 1994;76(5):789-92. Not test of device.
172 Gent M, Hirsh J, Ginsberg JS, et al. Low-molecular-weight heparinoid orgaran is more effective than aspirin in the prevention of venous thromboembolism after surgery for hip fracture. Circulation. Jan. 1. 1996;93(1):80-4. Not test of device. [pmid: 8616946].
173 Gent M, Roberts RS. A meta-analysis of the studies of dihydroergotamine plus heparin in the prophylaxis of deep vein thrombosis. Chest. May. 1986;89(5 Suppl):396S-400S. Not a test of device or US device. [pmid: 3516587].
174 Giannoudis PV, Smith RM, Bellamy MC, et al. Stimulation of the inflammatory system by reamed and unreamed nailing of femoral fractures. An analysis of the second hit. Journal of Bone & Joint Surgery - British Volume. Mar. 1999;81(2):356-61. Not hip fracture.
175 Gillespie WJ, Avenell A, Henry DA, et al. Vitamin D and vitamin D analogues for preventing fractures associated with involutional and post-menopausal osteoporosis.[update in Cochrane Database Syst Rev. 2005;(3):CD000227; PMID: 16034849][update of Cochrane Database Syst Rev. 2000;(2):CD000227; PMID: 10796331]. Cochrane Database of Systematic Reviews. 2001;(1):CD000227. Not RCT. [pmid: 11279685].
176 Gillespie WJ, Walenkamp G. Antibiotic prophylaxis for surgery for proximal femoral and other closed long bone fractures.[update in Cochrane Database Syst Rev. 2001;(1):CD000244; PMID: 11279687]. Cochrane Database of Systematic Reviews. 2000;(2):CD000244. Duplicate. [pmid: 10796333].
177 Gillespie WJ, Walenkamp G. Antibiotic prophylaxis for surgery for proximal femoral and other closed long bone fractures.[update of Cochrane Database Syst Rev. 2000;(2):CD000244; PMID: 10796333]. Cochrane Database of Systematic Reviews. 2001;(1):CD000244. Not RCT. [pmid: 11279687].
178 Gitelis S, Neel MD, Wilkins RM, et al. The use of a closed expandable prosthesis for pediatric sarcomas. Chirurgia Degli Organi di Movimento. Oct-Dec. 2003;88(4):327-33. Not hip fracture. [pmid: 15259547].
179 Gogus A, Ozturk C, Tezer M, et al. “Sandwich technique” in the surgical treatment of primary complex fractures of the femur and humerus. International Orthopaedics. Feb. 2007;31(1):87-92. Not hip fracture. [pmid: 16691386].
180 Goodman SB, Davidson JA, Locke L, et al. A biomechanical study of two methods of internal fixation of unstable fractures of the femoral neck. A preliminary study. Journal of Orthopaedic Trauma. 1992;6(1):66-72. Not patient population. [pmid: 1556626].
181 Goodwin R, Mahar AT, Oka R, et al. Biomechanical evaluation of retrograde intramedullary stabilization for femoral fractures: the effect of fracture level. Journal of Pediatric Orthopedics. Dec. 2007;27(8):873-6. Not patient population. [pmid: 18209606].
182 Gopal S, Giannoudis PV. Prospective randomized study of reamed versus unreamed femoral intramedullary nailing: an assessment of procedures.[comment]. Journal of Orthopaedic Trauma. Aug. 2001;15(6):458-60. Not hip fracture. [pmid: 11514783].
183 Gosling T, Hufner T, Westphal R, et al. Overdistraction of the fracture eases reduction in delayed femoral nailing: results of intraoperative force measurements. Journal of Trauma-Injury Infection & Critical Care. Oct. 2006;61(4):900-4. Not hip fracture.
184 Gotfried Y. Percutaneous compression plating for intertrochanteric hip fractures: treatment rationale. Orthopedics. Jun. 2002;25(6):647-52. Not RCT. [pmid: 12083574].
185 Gotze C, Tschugunow A, Gotze HG, et al. Long-term results of the metal-cancellous cementless Lubeck total hip arthroplasty: a critical review at 12.8 years. Archives of Orthopaedic & Trauma Surgery. Jan. 2006;126(1):28-35. Not RCT. [pmid: 16283343].
186 Grecula MJ, Thomas JA, Kreuzer SW. Impact of implant design on femoral head hemiresurfacing arthroplasty. Clinical Orthopaedics & Related Research. Jan. 2004;(418):41-7. Not RCT. [pmid: 15043091].
187 Green D, Hirsh J, Heit J, et al. Low molecular weight heparin: a critical analysis of clinical trials. Pharmacological Reviews. Mar. 1994;46(1):89-109. Not test of device. [pmid: 8190751].
188 Gregory P, Sullivan JA, Herndon WA. Adolescent femoral shaft fractures: rigid versus flexible nails. Orthopedics. Jul. 1995;18(7):645-9. Not hip fracture. [pmid: 7479403].
189 Grover J, Wiss DA. A prospective study of fractures of the femoral shaft treated with a static, intramedullary, interlocking nail comparing one versus two distal screws. Orthopedic Clinics of North America. Jan. 1995;26(1):139-46. Not hip fracture. [pmid: 7838494].
190 Grutzner PA, Suhm N. Computer aided long bone fracture treatment. Injury. Jun. 2004;35(Suppl 1):S-A57-64. Not hip fracture.
191 Gundle R, Gargan MF, Simpson AH. How to minimize failures of fixation of unstable intertrochanteric fractures. Injury. Nov. 1995;26(9):611-4. Not RCT. [pmid: 8550168].
192 Gusi N, Raimundo A, Leal A. Low-frequency vibratory exercise reduces the risk of bone fracture more than walking: a randomized controlled trial. BMC Musculoskeletal Disorders. 2006;7:92. Not a test of device or US device. [pmid: 17137514].
193 Haentjens P. Thromboembolic prophylaxis in orthopaedic trauma patients: a comparison between a fixed dose and an individually adjusted dose of a low molecular weight heparin (nadroparin calcium)[see comment]. Injury. Jul. 1996;27(6):385-90. Not test of device. [pmid: 8881132].
194 Haentjens P, Autier P, Barette M, et al. Costs of care after hospital discharge among women with a femoral neck fracture. Clinical Orthopaedics & Related Research. Sep. 2003;(414):250-8. Not RCT. [pmid: 12966300].
195 Haentjens P, Autier P, Barette M, et al. Predictors of functional outcome following intracapsular hip fracture in elderly women. A one-year prospective cohort study. Injury. Jul. 2005;36(7):842-50. Not RCT. [pmid: 15949486].
196 Haentjens P, Autier P, Collins J, et al. Colles fracture, spine fracture, and subsequent risk of hip fracture in men and women. A meta-analysis. Journal of Bone & Joint Surgery - American Volume. Oct. 2003;85-A(10):1936-43. Not RCT.
197 Haentjens P, Lamraski G. Endoprosthetic replacement of unstable, comminuted intertrochanteric fracture of the femur in the elderly, osteoporotic patient: a review. Disability & Rehabilitation. Sep 30-Oct 15. 2005;27(18–19):1167-80. Not RCT. [pmid: 16278186].
198 Haidukewych G, Sems SA, Huebner D, et al. Results of polyaxial locked-plate fixation of periarticular fractures of the knee. Journal of Bone & Joint Surgery - American Volume. Mar. 2007;89(3):614-20. Not hip fracture.
199 Haidukewych GJ, Berry DJ. Salvage of failed internal fixation of intertrochanteric hip fractures. Clinical Orthopaedics & Related Research. Jul. 2003;(412):184-8. Not RCT. [pmid: 12838070].
200 Hamelinck HKM, Haagmans M, Snoeren MM, et al. Safety of computer-assisted surgery for cannulated hip screws. Clinical Orthopaedics & Related Research. Feb. 2007;455:241-5. Not patient population. [pmid: 16957645].
201 Hamilton BH, Hamilton VH. Estimating surgical volume--outcome relationships applying survival models: accounting for frailty and hospital fixed effects. Health Economics. Jul-Aug. 1997;6(4):383-95. Not RCT. [pmid: 9285231].
202 Hammacher ER, van Meeteren MC, van der Werken C. Improved results in treatment of femoral shaft fractures with the unreamed femoral nail? A multicenter experience. Journal of Trauma-Injury Infection & Critical Care. Sep. 1998;45(3):517-21. Not hip fracture.
203 Handoll HH, Parker MJ, Sherrington C. Mobilisation strategies after hip fracture surgery in adults.[update in Cochrane Database Syst Rev. 2004;(4):CD001704; PMID: 15495015][update of Cochrane Database Syst Rev. 2002;(2):CD001704; PMID: 12076418]. Cochrane Database of Systematic Reviews. 2003;(1):CD001704. Duplicate. [pmid: 12535411].
204 Handoll HHG, Sherrington C. Mobilisation strategies after hip fracture surgery in adults.[update of Cochrane Database Syst Rev. 2004;(4):CD001704; PMID: 15495015]. Cochrane Database of Systematic Reviews. 2007;(1):CD001704. Not RCT. [pmid: 17253462].
205 Handoll HHG, Sherrington C, Parker MJ. Mobilisation strategies after hip fracture surgery in adults.[update in Cochrane Database Syst Rev. 2007;(1):CD001704; PMID: 17253462][update of Cochrane Database Syst Rev. 2003;(1):CD001704; PMID: 12535411]. Cochrane Database of Systematic Reviews. 2004;(4):CD001704. Duplicate. [pmid: 15495015].
206 Hardern RD, Sutcliffe J. No more 'routine' chest radiographs in patients with proximal femoral fractures?. European Journal of Emergency Medicine. Jun. 1994;1(2):78-9. Not RCT. [pmid: 9422142].
207 Hardwick ME, Colwell CW Jr. Advances in DVT prophylaxis and management in major orthopaedic surgery. Surgical Technology International. 2004;12:265-8. Not RCT. [pmid: 15455336].
208 Hardy DCR, Frassinet P. Hydroxyapatite-coated femoral arthroplasties: a long-term study through 29 Corail prostheses explanted during a ten-year survey. Surgical Technology International. Sep. 2002;10:237-45. Not RCT. [pmid: 12384887].
209 Harris T, Ruth JT, Szivek J, et al. The effect of implant overlap on the mechanical properties of the femur. Journal of Trauma-Injury Infection & Critical Care. May. 2003;54(5):930-5. Not patient population.
210 Hartin NL, Harris I, Hazratwala K. Retrograde nailing versus fixed-angle blade plating for supracondylar femoral fractures: a randomized controlled trial. ANZ Journal of Surgery. May. 2006;76(5):290-4. Not hip fracture. [pmid: 16768683].
211 Haynes RC, Poll RG, Miles AW, et al. An experimental study of the failure modes of the Gamma Locking Nail and AO Dynamic Hip Screw under static loading: a cadaveric study. Medical Engineering & Physics. Jul. 1997;19(5):446-53. Not patient population. [pmid: 9338885].
212 Heck BE, Ebraheim NA, Foetisch C. Direct complications of trochanteric osteotomy in open reduction and internal fixation of acetabular fractures. American Journal of Orthopedics. Feb. 1997;26(2):124-8. Not hip fracture. [pmid: 9040886].
213 Hedin H, Borgquist L, Larsson S. A cost analysis of three methods of treating femoral shaft fractures in children: a comparison of traction in hospital, traction in hospital/home and external fixation. Acta Orthopaedica Scandinavica. Jun. 2004;75(3):241-8. Not hip fracture. [pmid: 15260413].
214 Hedlundh U, Ahnfelt L, Hybbinette CH, et al. Dislocations and the femoral head size in primary total hip arthroplasty. Clinical Orthopaedics & Related Research. Dec. 1996;(333):226-33. Not RCT. [pmid: 8981900].
215 Hedstrom SA, Lidgren L, Sernbo I, et al. Cefuroxime prophylaxis in trochanteric hip fracture operations. Acta Orthopaedica Scandinavica. Aug. 1987;58(4):361-4. Not test of device. [pmid: 3673526].
216 Heetveld MJ, Raaymakers ELFB, Luitse JSK, et al. Rating of internal fixation and clinical outcome in displaced femoral neck fractures: a prospective multicenter study. Clinical Orthopaedics & Related Research. Jan. 2007;454:207-13. Not RCT. [pmid: 17031315].
217 Heetveld MJ, Raaymakers ELFB, Luitse JSK, et al. Femoral neck fractures: can physiologic status determine treatment choice?. Clinical Orthopaedics & Related Research. Aug. 2007;461:203-12. Not RCT. [pmid: 17414163].
218 Heetveld MJ, Raaymakers ELFB, van Eck-Smit BL, et al. Internal fixation for displaced fractures of the femoral neck. Does bone density affect clinical outcome?. Journal of Bone & Joint Surgery - British Volume. Mar. 2005;87(3):367-73. Not RCT.
219 Heetveld MJ, Raaymakers ELFB, van Walsum ADP, et al. Observer assessment of femoral neck radiographs after reduction and dynamic hip screw fixation. Archives of Orthopaedic & Trauma Surgery. Apr. 2005;125(3):160-5. Not RCT. [pmid: 15742193].
220 Heller KD, Zilkens KW, Cohen B, et al. Compound osteosynthesis of pathological fractures of the proximal femoral shaft. Experimental studies on the biomechanical effects of additional intramedullary splinting. Archives of Orthopaedic & Trauma Surgery. 1996;115(2):115-7. Not hip fracture. [pmid: 9063850].
221 Helttula I, Karanko M, Gullichsen E. Similar central hemodynamics but increased postoperative oxygen consumption in unreamed versus reamed intramedullary nailing of femoral fractures. Journal of Trauma-Injury Infection & Critical Care. Nov. 2006;61(5):1178-85. Not hip fracture.
222 Hemmingsen C, Nielsen JE. Intravenous ketamine for prevention of severe hypotension during spinal anaesthesia. Acta Anaesthesiologica Scandinavica. Nov. 1991;35(8):755-7. Not a test of device or US device. [pmid: 1763596].
223 Henley E. Can low-dose aspirin prevent thromboembolic phenomena in patients undergoing surgery for hip fracture or elective arthroplasty?. Journal of Family Practice. Jul. 2000;49(7):598-9. Not test of device. [pmid: 10923565].
224 Hernefalk L, Granstrom P, Messner K. Sequential scintigraphy and orthoradiographic measurement of femoral shortening after femoral neck fracture. Archives of Orthopaedic & Trauma Surgery. 1997;116(4):198-203. Not RCT. [pmid: 9128771].
225 Hernefalk L, Messner K. Rigid osteosynthesis decreases the late complication rate after femoral neck fracture. The influence of three different osteosynthesis devices evaluated in 369 patients. Archives of Orthopaedic & Trauma Surgery. 1996;115(2):71-4. Not RCT. [pmid: 9063855].
226 Hernefalk L, Messner K. In vitro femoral stiffness after femoral neck osteotomy and osteosynthesis with defined surgical errors. Journal of Orthopaedic Trauma. 1996;10(6):416-20. Not RCT. [pmid: 8854320].
227 Hernigou P, Charpentier P. Routine use of adjusted low-dose oral anticoagulants during the first three postoperative months after hip fracture in patients without comorbidity factors. Journal of Orthopaedic Trauma. Nov. 2001;15(8):535-41. Not RCT. [pmid: 11733668].
228 Herrick C, Steger-May K, Sinacore DR, et al. Persistent pain in frail older adults after hip fracture repair. Journal of the American Geriatrics Society. Dec. 2004;52(12):2062-8. Not RCT. [pmid: 15571543].
229 Herscovici D Jr, Ricci WM, McAndrews P, et al. Treatment of femoral shaft fracture using unreamed interlocked nails. Journal of Orthopaedic Trauma. Jan. 2000;14(1):10-4. Not hip fracture. [pmid: 10630796].
230 Higgins JPT, Thompson SG. Quantifying heterogeneity in a meta-analysis. Statistics in Medicine. Jun. 15. 2002;21(11):1539-58. Not hip fracture. [pmid: 12111919].
231 Higuera CA, Hanna G, Florjancik K, et al. The use of proximal fixed modular stems in revision of total hip arthroplasty. Journal of Arthroplasty. Jun. 2006;21(4 Suppl 1):112-6. Not RCT. [pmid: 16781443].
232 Holmberg S, Mattsson P, Dahlborn M, et al. Fixation of 220 femoral neck fractures. A prospective comparison of the Rydell nail and the LIH hook pins. Acta Orthopaedica Scandinavica. Apr. 1990;61(2):154-7. Not included device. [pmid: 2360434].
233 Homik J, Cranney A, Shea B, et al. Bisphosphonates for steroid induced osteoporosis. Cochrane Database of Systematic Reviews. 2000;(2):CD001347. Not hip fracture. [pmid: 10796432].
234 Homik J, Suarez-Almazor ME, Shea B, et al. Calcium and vitamin D for corticosteroid-induced osteoporosis. Cochrane Database of Systematic Reviews. 2000;(2):CD000952. Not hip fracture. [pmid: 10796394].
235 Hood G, Edbrooke DL, Gerrish SP. Postoperative analgesia after triple nerve block for fractured neck of femur.[see comment]. Anaesthesia. Feb. 1991;46(2):138-40. Not a test of device or US device. [pmid: 1872429].
236 Hornby R, Evans JG, Vardon V. Operative or conservative treatment for trochanteric fractures of the femur. A randomised epidemiological trial in elderly patients. Journal of Bone & Joint Surgery - British Volume. Aug. 1989;71(4):619-23. Other exclusion - conservative treatment for one arm.
237 Hui AC, Anderson GH, Choudhry R, et al. Internal fixation or hemiarthroplasty for undisplaced fractures of the femoral neck in octogenarians. Journal of Bone & Joint Surgery - British Volume. Nov. 1994;76(6):891-4. Not RCT.
238 Hull JB, Bell MJ. Modern trends for external fixation of fractures in children: a critical review. Journal of Pediatric Orthopaedics, Part B. Apr. 1997;6(2):103-9. Not hip fracture. [pmid: 9165438].
239 Hull JB, Sanderson PL, Rickman M, et al. External fixation of children's fractures: use of the Orthofix Dynamic Axial Fixator. Journal of Pediatric Orthopaedics, Part B. Jul. 1997;6(3):203-6. Not hip fracture. [pmid: 9260650].
240 Huusko TM, Karppi P, Avikainen V, et al. Intensive geriatric rehabilitation of hip fracture patients: a randomized, controlled trial. Acta Orthopaedica Scandinavica. Aug. 2002;73(4):425-31. Not test of device. [pmid: 12358116].
241 Huusko TM, Karppi P, Kautiainen H, et al. Randomized, double-blind, clinically controlled trial of intranasal calcitonin treatment in patients with hip fracture. Calcified Tissue International. Dec. 2002;71(6):478-84. Not test of device. [pmid: 12370798].
242 Iannacone WM, Bennett FS, DeLong WG Jr, et al. Initial experience with the treatment of supracondylar femoral fractures using the supracondylar intramedullary nail: a preliminary report. Journal of Orthopaedic Trauma. Aug. 1994;8(4):322-7. Not hip fracture. [pmid: 7965294].
243 Iida Y, Kuroda T, Kitano T, et al. Dexa-measured bone density changes over time after intertrochanteric hip fractures. Kobe Journal of Medical Sciences. Apr. 2000;46(1–2):1-12. Not RCT. [pmid: 11193499].
244 Ingman AM. Percutaneous intramedullary fixation of trochanteric fractures of the femur. Clinical trial of a new hip nail. Injury. Sep. 2000;31(7):483-7. Not RCT. [pmid: 10908740].
245 Ingman AM. Development of small diameter intramedullary nails made from ISO 5832–9 stainless steel. Australian & New Zealand Journal of Surgery. Mar. 2000;70(3):221-5. Not hip fracture. [pmid: 10765908].
246 Iorio R, Schwartz B, Macaulay W, et al. Surgical treatment of displaced femoral neck fractures in the elderly: a survey of the American Association of Hip and Knee Surgeons. Journal of Arthroplasty. Dec. 2006;21(8):1124-33. Not RCT. [pmid: 17162171].
247 Ippolito E, Bray EW, Corsi A, et al. Natural history and treatment of fibrous dysplasia of bone: a multicenter clinicopathologic study promoted by the European Pediatric Orthopaedic Society. Journal of Pediatric Orthopaedics, Part B. May. 2003;12(3):155-77. Not hip fracture. [pmid: 12703030].
248 Ippolito E, Caterini R, Farsetti P, et al. Surgical treatment of fibrous dysplasia of bone in McCune- Albright syndrome. Journal of Pediatric Endocrinology. 2002;15(Suppl 3):939-44. Not hip fracture.
249 Isakov E. Gait rehabilitation: a new biofeedback device for monitoring and enhancing weight-bearing over the affected lower limb. Europa Medicophysica. Mar. 2007;43(1):21-6. Not RCT. [pmid: 17021589].
250 Ishii Y, Terajima K, Terashima S, et al. Joint proprioception in the elderly with and without hip fracture. Journal of Orthopaedic Trauma. Nov. 2000;14(8):542-5. Not RCT. [pmid: 11149499].
251 Ishii Y, Tojo T, Terajima K, et al. Intracapsular components do not change hip proprioception. Journal of Bone & Joint Surgery - British Volume. Mar. 1999;81(2):345-8. Not RCT.
252 Isiklar ZU, Demirors H, Akpinar S, et al. Two-stage treatment of chronic staphylococcal orthopaedic implant-related infections using vancomycin impregnated PMMA spacer and rifampin containing antibiotic protocol. Bulletin of the Hospital for Joint Diseases. 1999;58(2):79-85. Not hip fracture.
253 Izumi H, Torisu T, Itonaga I, et al. Joint motion of bipolar femoral prostheses. Journal of Arthroplasty. Apr. 1995;10(2):237-43. Not RCT. [pmid: 7798107].
254 Jablonski M, Gorzelak M, Kuczynski P, et al. Less invasive posterior surgical approach for hip joint replacement--complications and limitations. Ortopedia Traumatologia Rehabilitacja. Jan-Feb. 2007;9(1):25-30. Not RCT.
255 Jacobsson B, Dalen N. Femoral head vitality after peroperative impaction of hip fractures. Acta Orthopaedica Scandinavica. Aug. 1985;56(4):312-3. Other exclusions. [pmid: 4072647].
256 Jacobsson B, Dalen N, Jonsson B, et al. Intraarticular pressure during operation of cervical hip fractures. Acta Orthopaedica Scandinavica. Feb. 1988;59(1):16-8. Not RCT. [pmid: 3354317].
257 Jain R, Koo M, Kreder HJ, et al. Comparison of early and delayed fixation of subcapital hip fractures in patients sixty years of age or less.[see comment]. Journal of Bone & Joint Surgery - American Volume. Sep. 2002;84-A(9):1605-12. Not RCT.
258 Jalovaara P, Berglund-Roden M, Wingstrand H, et al. Treatment of hip fracture in Finland and Sweden. Prospective comparison of 788 cases in three hospitals. Acta Orthopaedica Scandinavica. Oct. 1992;63(5):531-5. Not RCT. [pmid: 1441950].
259 Janku GV, Paiement GD, Green HD. Prevention of venous thromboembolism in orthopaedics in the United States. Clinical Orthopaedics & Related Research. Apr. 1996;(325):313-21. Not hip fracture. [pmid: 8998892].
260 Jazrawi LM, Kummer FJ, Simon JA, et al. New technique for treatment of unstable distal femur fractures by locked double-plating: case report and biomechanical evaluation.[see comment]. Journal of Trauma-Injury Infection & Critical Care. Jan. 2000;48(1):87-92. Not hip fracture.
261 Jette AM, Harris BA, Cleary PD, et al. Functional recovery after hip fracture. Archives of Physical Medicine & Rehabilitation. Oct. 1987;68(10):735-40. Not RCT. [pmid: 3662784].
262 Jones HW, Johnston P, Parker M. Are short femoral nails superior to the sliding hip screw? A meta-analysis of 24 studies involving 3,279 fractures. International Orthopaedics. Apr. 2006;30(2):69-78. Not RCT. [pmid: 16496147].
263 Jones S, DiPiro JT, Nix DE, et al. Cephalosporins for prophylaxis in operative repair of femoral fractures. Levels in serum, muscle, and hematoma. Journal of Bone & Joint Surgery - American Volume. Jul. 1985;67(6):921-4. Not test of device.
264 Jones SF, White A. Analgesia following femoral neck surgery. Lateral cutaneous nerve block as an alternative to narcotics in the elderly. Anaesthesia. Jul. 1985;40(7):682-5. Not test of device. [pmid: 3896019].
265 Jonsson B, Sernbo I, Johnell O. Rehabilitation of hip fracture patients with Parkinson's Disease. Scandinavian Journal of Rehabilitation Medicine. Dec. 1995;27(4):227-30. Not RCT. [pmid: 8650507].
266 Juelsgaard P, Sand NP, Felsby S, et al. Perioperative myocardial ischaemia in patients undergoing surgery for fractured hip randomized to incremental spinal, single-dose spinal or general anaesthesia. European Journal of Anaesthesiology. Nov. 1998;15(6):656-63. Not test of device. [pmid: 9884850].
267 Juhn A, Krimerman J, Mendes DG. Intertrochanteric fracture of the hip. Comparison of nail-plate fixation and Ender's nailing. Archives of Orthopaedic & Traumatic Surgery. 1988;107(3):136-9. Not included device.
268 Jukkala-Partio K, Partio EK, Helevirta P, et al. Treatment of subcapital femoral neck fractures with bioabsorbable or metallic screw fixation. A preliminary report. Annales Chirurgiae et Gynaecologiae. 2000;89(1):45-52. Not RCT. [pmid: 10791645].
269 Kakar S, Tornetta P 3rd, Schemitsch EH, et al. Technical considerations in the operative management of femoral neck fractures in elderly patients: a multinational survey. Journal of Trauma-Injury Infection & Critical Care. Sep. 2007;63(3):641-6. Not RCT.
270 Kanai H, Igarashi M, Yamamoto S, et al. Spontaneous subcapital femoral neck fracture complicating a healed intertrochanteric fracture. Archives of Orthopaedic & Trauma Surgery. 1999;119(5–6):271-5. Not RCT. [pmid: 10447621].
271 Kanaji A, Higashi M, Namisato M, et al. Trochanteric hip fracture in an elderly patient with leprosy during osteoporosis treatment with risedronate and alfacalcidol. Journal of Bone & Mineral Metabolism. 2005;23(1):90-4. Not RCT. [pmid: 15616900].
272 Kapukaya A, Subasi M, Necmioglu S, et al. Treatment of closed femoral diaphyseal fractures with external fixators in children. Archives of Orthopaedic & Trauma Surgery. 1998;117(6–7):387-9. Not hip fracture. [pmid: 9709858].
273 Karachalios T, Lyritis G, Hatzopoulos E, et al. Single-dose prophylaxis of ceftriaxone versus standard dosage of cefotaxime in the prophylaxis of bacterial complications in orthopedic surgery. Chemioterapia. Jun. 1987;6(2 Suppl):573-5. Not test of device. [pmid: 3334628].
274 Karn NK, Singh GK, Kumar P, et al. Comparison between external fixation and sliding hip screw in the management of trochanteric fracture of the femur in Nepal.[erratum appears in J Bone Joint Surg Br. 2007 Mar;89(3):421]. Journal of Bone & Joint Surgery - British Volume. Oct. 2006;88(10):1347-50. Not included device.
275 Karpos PA, McFerran MA, Johnson KD. Intramedullary nailing of acute femoral shaft fractures using manual traction without a fracture table. Journal of Orthopaedic Trauma. Feb. 1995;9(1):57-62. Not hip fracture. [pmid: 7714655].
276 Katelaris AG, Cumming RG. Health status before and mortality after hip fracture. American Journal of Public Health. Apr. 1996;86(4):557-60. Not RCT. [pmid: 8604790].
277 Kauffman JI, Simon JA, Kummer FJ, et al. Internal fixation of femoral neck fractures with posterior comminution: a biomechanical study. Journal of Orthopaedic Trauma. Mar-Apr. 1999;13(3):155-9. Not patient population. [pmid: 10206245].
278 Kaukonen JP, Tuomainen P, Makijarvi J, et al. Intravenous cefuroxime prophylaxis. Tissue levels after one 3-gram dose in 40 cases of hip fracture. Acta Orthopaedica Scandinavica. Feb. 1995;66(1):14-6. Not RCT. [pmid: 7863760].
279 Kayali C, Agus H, Turgut A. Successful results of minimally invasive surgery for comminuted supracondylar femoral fractures with LISS: comparative study of multiply injured and isolated femoral fractures. Journal of Orthopaedic Science. Sep. 2007;12(5):458-65. Not hip fracture. [pmid: 17909931].
280 Kazemi AP, Zand F, Sedaghat M. Blood-sparing efficiency of transdermal nitroglycerine during open fixation of femur shaft fractures: a randomized, double-blind study. Journal of Clinical Anesthesia. Nov. 2006;18(7):495-8. Not hip fracture. [pmid: 17126776].
281 Kenzora JE, Magaziner J, Hudson J, et al. Outcome after hemiarthroplasty for femoral neck fractures in the elderly. Clinical Orthopaedics & Related Research. Mar. 1998;(348):51-8. Not RCT. [pmid: 9553533].
282 Keong N, Ricketts D, Alakeson N, et al. Pressure sores following elective total hip arthroplasty: pitfalls of misinterpretation. Annals of the Royal College of Surgeons of England. May. 2004;86(3):174-6. Not hip fracture. [pmid: 15140301].
283 Khan RJK, MacDowell A, Crossman P, et al. Cemented or uncemented hemiarthroplasty for displaced intracapsular fractures of the hip--a systematic review. Injury. Jan. 2002;33(1):13-7. Not RCT. [pmid: 11879826].
284 Khasraghi FA, Christmas C, Lee EJ, et al. Effectiveness of a multidisciplinary team approach to hip fracture management. Journal of Surgical Orthopaedic Advances. 2005;14(1):27-31. Not RCT. [pmid: 15766439].
285 Kim Y-H, Oh SH, Kim JS, et al. Contemporary total hip arthroplasty with and without cement in patients with osteonecrosis of the femoral head. Journal of Bone & Joint Surgery - American Volume. Apr. 2003;85-A(4):675-81. Not hip fracture.
286 Kim YS, Callaghan JJ, Kwon SY, et al. Arthroplasty of the hip in patients with aplastic anemia. Journal of Bone & Joint Surgery - American Volume. Sep. 2000;82(9):1231-9. Not hip fracture.
287 Kirschenbaum IH. The displaced femoral neck fracture: internal fixation versus bipolar endoprosthesis. Results of a prospective, randomized comparison. Clinical Orthopaedics & Related Research. Mar. 1989;(240):311-2. Not RCT. [pmid: 2917443].
288 Kirschner MH, Brauns L, Gonschorek O, et al. Vascularised knee joint transplantation in man: the first two years experience. European Journal of Surgery. Apr. 2000;166(4):320-7. Not hip fracture. [pmid: 10817331].
289 Kligman M, Zecevic M, Roffman M. The effect of intramedullary corticocancellous bone plug for hip hemiarthroplasty. Journal of Trauma-Injury Infection & Critical Care. Jul. 2001;51(1):84-7. Not RCT.
290 Koo K-H, Ha Y-C, Jung WH, et al. Isolated fracture of the ceramic head after third-generation alumina-on-alumina total hip arthroplasty. Journal of Bone & Joint Surgery - American Volume. Feb. 2008;90(2):329-36. Not RCT.
291 Kose N, Gunal I, Wang X, et al. Setscrew distal locking for intramedullary nails: a biomechanical study. Journal of Orthopaedic Trauma. Aug. 2000;14(6):414-9. Not hip fracture. [pmid: 11001415].
292 Koval KJ, Egol KA, Hiebert R, et al. Tape blisters after hip surgery: can they be eliminated completely?. American Journal of Orthopedics. May. 2007;36(5):261-5. Not test of device. [pmid: 17571831].
293 Koval KJ, Hoehl JJ, Kummer FJ, et al. Distal femoral fixation: a biomechanical comparison of the standard condylar buttress plate, a locked buttress plate, and the 95-degree blade plate. Journal of Orthopaedic Trauma. Oct. 1997;11(7):521-4. Not hip fracture. [pmid: 9334954].
294 Koval KJ, Kummer FJ, Bharam S, et al. Distal femoral fixation: a laboratory comparison of the 95 degrees plate, antegrade and retrograde inserted reamed intramedullary nails. Journal of Orthopaedic Trauma. 1996;10(6):378-82. Not hip fracture. [pmid: 8854314].
295 Krettek C, Blauth M, Miclau T, et al. Accuracy of intramedullary templates in femoral and tibial radiographs. Journal of Bone & Joint Surgery - British Volume. Nov. 1996;78(6):963-4. Not hip fracture.
296 Krettek C, Schandelmaier P, Miclau T, et al. Minimally invasive percutaneous plate osteosynthesis (MIPPO) using the DCS in proximal and distal femoral fractures. Injury. 1997;28(Suppl 1):A20-30. Not RCT. [pmid: 10897284].
297 Kropfl A, Berger U, Neureiter H, et al. Intramedullary pressure and bone marrow fat intravasation in unreamed femoral nailing. Journal of Trauma-Injury Infection & Critical Care. May. 1997;42(5):946-54. Not hip fracture.
298 Kuhlman JE, Fishman EK, Leichner PK, et al. Skeletal metastases from hepatoma: frequency, distribution, and radiographic features. Radiology. Jul. 1986;160(1):175-8. Not hip fracture. [pmid: 3012630].
299 Kumar MM, Sudhakar GM, Shah DD, et al. A study of the role of osteotomy in unstable intertrochanteric fractures. Journal of Postgraduate Medicine. Jan-Mar. 1996;42(1):4-6. Not test of device. [pmid: 9715288].
300 Kwong LM. Deep vein thrombosis prophylaxis: better living through chemistry--in the affirmative.[see comment]. Journal of Arthroplasty. Jun. 2005;20(4 Suppl 2):12-4. Not RCT. [pmid: 15991121].
301 Kwong LM, Muntz JE. Thromboprophylaxis dosing: the relationship between timing of first administration, efficacy, and safety. American Journal of Orthopedics. Nov. 2002;31(11 Suppl):16-20. Not test of device. [pmid: 12463579].
302 Laing AC, Tootoonchi I, Hulme PA, et al. Effect of compliant flooring on impact force during falls on the hip. Journal of Orthopaedic Research. Jul. 2006;24(7):1405-11. Not RCT. [pmid: 16705716].
303 Lamb SE, Oldham JA, Morse RE, et al. Neuromuscular stimulation of the quadriceps muscle after hip fracture: a randomized controlled trial. Archives of Physical Medicine & Rehabilitation. Aug. 2002;83(8):1087-92. Not test of device. [pmid: 12161829].
304 Lampotang S, Gravenstein JS, Euliano TY, et al. Influence of pulse oximetry and capnography on time to diagnosis of critical incidents in anesthesia: a pilot study using a full-scale patient simulator. Journal of Clinical Monitoring & Computing. Jul. 1998;14(5):313-21. Not hip fracture. [pmid: 9951756].
305 Lane NE, Williams EN, Hung Y-Y, et al. Association of nitrate use with risk of new radiographic features of hip osteoarthritis in elderly white women: the study of osteoporotic fractures. Arthritis & Rheumatism. Dec. 15. 2003;49(6):752-8. Not hip fracture. [pmid: 14673960].
306 Lang S, Livesley MA, Lambert PA, et al. The genomic diversity of coagulase-negative staphylococci associated with nosocomial infections. Journal of Hospital Infection. Nov. 1999;43(3):187-93. Not hip fracture. [pmid: 10582185].
307 Laufer Y, Lahav M, Lenger R, et al. Functional recovery following pertrochanteric hip fractures fixated with the Dynamic Hip Screw vs. the percutaneous compression plate. Thescientificworldjournal. Mar. 19. 2005;5:221-9. Not RCT. [pmid: 15798882].
308 Lee AYY, Gent M, Julian JA, et al. Bilateral vs. ipsilateral venography as the primary efficacy outcome measure in thromboprophylaxis clinical trials: a systematic review. Journal of Thrombosis & Haemostasis. Oct. 2004;2(10):1752-9. Not RCT. [pmid: 15456486].
309 Lee P-C, Hsieh P-H, Yu S-W, et al. Biologic plating versus intramedullary nailing for comminuted subtrochanteric fractures in young adults: a prospective, randomized study of 66 cases. Journal of Trauma-Injury Infection & Critical Care. Dec. 2007;63(6):1283-91. Not patient population.
310 Lee P-C, Yu S-w, Hsieh P-H, et al. Bridge-plating osteosynthesis of 20 comminuted subtrochanteric fractures with dynamic hip screw. Chang Gung Medical Journal. Dec. 2002;25(12):803-10. Not RCT. [pmid: 12635836].
311 Lee Y-S, Chen S-H, Tsuang Y-H, et al. Internal fixation of undisplaced femoral neck fractures in the elderly: a retrospective comparison of fixation methods. Journal of Trauma-Injury Infection & Critical Care. Jan. 2008;64(1):155-62. Not RCT.
312 Leggon RE, Feldmann DD. Retrograde femoral nailing: a focus on the knee. American Journal of Knee Surgery. 2001;14(2):109-18. Not hip fracture. [pmid: 11401168].
313 Lenich A, Fierlbeck J, Al-Munajjed A, et al. First clinical and biomechanical results of the Trochanteric Fixation Nail (TFN). Technology & Health Care. 2006;14(4–5):403-9. Not RCT. [pmid: 17065761].
314 Lenzner A, Kaur I, Haviko T, et al. Impaction bone-grafting increases the holding power of cancellous screws in the femoral head. A pull-out study in human cadaver hips. Acta Orthopaedica Scandinavica. Feb. 1999;70(1):25-8. Not hip fracture. [pmid: 10191743].
315 Leung KS, Chen CM, So WS, et al. Multicenter trial of modified Gamma nail in East Asia. Clinical Orthopaedics & Related Research. Feb. 1996;(323):146-54. Not RCT. [pmid: 8625572].
316 Levitsky J, Te HS, Cohen SM. The safety and outcome of joint replacement surgery in liver transplant recipients. Liver Transplantation. Apr. 2003;9(4):373-6. Not RCT. [pmid: 12682889].
317 Licciardone JC, Stoll ST, Cardarelli KM, et al. A randomized controlled trial of osteopathic manipulative treatment following knee or hip arthroplasty.[see comment]. Journal of the American Osteopathic Association. May. 2004;104(5):193-202. Not hip fracture. [pmid: 15176518].
318 Lieberman D, Galinsky D, Fried V, et al. Factors affecting the results of the clock drawing test in elderly patients hospitalized for physical rehabilitation. International Journal of Geriatric Psychiatry. May. 1999;14(5):325-30. Not RCT. [pmid: 10389034].
319 Lindahl H, Malchau H, Oden A, et al. Risk factors for failure after treatment of a periprosthetic fracture of the femur. Journal of Bone & Joint Surgery - British Volume. Jan. 2006;88(1):26-30. Not RCT.
320 Lindequist S, Malmqvist B, Ullmark G. Fixation of femoral neck fracture. Prospective comparison of von Bahr screws, Gouffon screws, and Hessel pins.[erratum appears in Acta Orthop Scand 1989 Aug;60(4):507–8]. Acta Orthopaedica Scandinavica. Jun. 1989;60(3):293-8. Not included device. [pmid: 2750502].
321 Lozman J, Deno DC, Feustel PJ, et al. Pulmonary and cardiovascular consequences of immediate fixation or conservative management of long-bone fractures. Archives of Surgery. Sep. 1986;121(9):992-9. Not hip fracture. [pmid: 3741107].
322 Lunsjo K, Ceder L, Stigsson L, et al. One-way compression along the femoral shaft with the Medoff sliding plate. The first European experience of 104 intertrochanteric fractures with a 1-year follow-up. Acta Orthopaedica Scandinavica. Aug. 1995;66(4):343-6. Not RCT. [pmid: 7676823].
323 Lunsjo K, Ceder L, Stigsson L, et al. Two-way compression along the shaft and the neck of the femur with the Medoff sliding plate: one-year follow-up of 108 intertrochanteric fractures. Journal of Bone & Joint Surgery - British Volume. May. 1996;78(3):387-90. Not RCT.
324 Luthje P, Nurmi I, Aho H, et al. Single-dose antibiotic prophylaxis in osteosynthesis for hip fractures. A clinical multicentre study in Finland. Annales Chirurgiae et Gynaecologiae. 2000;89(2):125-30. Not test of device. [pmid: 10905679].
325 Lu-Yao GL, Keller RB, Littenberg B, et al. Outcomes after displaced fractures of the femoral neck. A meta-analysis of one hundred and six published reports. Journal of Bone & Joint Surgery - American Volume. Jan. 1994;76(1):15-25. Not RCT.
326 Lyons AR. Clinical outcomes and treatment of hip fractures. American Journal of Medicine. Aug. 18. 1997;103(2A):51S-63S. discussion S-4S. Not RCT. [pmid: 9302897].
327 Lyritis GP, Johnell O. Orthopaedic management of hip fracture. Bone. 1993;14(Suppl 1):S11-7. Not RCT. [pmid: 8110514].
328 Macaulay W, Yoon RS, Parsley B, et al. Displaced femoral neck fractures: is there a standard of care?. Orthopedics. Sep. 2007;30(9):748-9. Not RCT. [pmid: 17899921].
329 Madsen JE, Naess L, Aune AK, et al. Dynamic hip screw with trochanteric stabilizing plate in the treatment of unstable proximal femoral fractures: a comparative study with the Gamma nail and compression hip screw. Journal of Orthopaedic Trauma. May. 1998;12(4):241-8. Duplicate, not RCT. [pmid: 9619458].
330 Mahaisavariya B, Laupattarakasem W. Ultrasound or image intensifier for closed femoral nailing. Journal of Bone & Joint Surgery - British Volume. Jan. 1993;75(1):66-8. Not RCT.
331 Mahoney CR, Fehringer EV, Kopjar B, et al. Femoral revision with impaction grafting and a collarless, polished, tapered stem. Clinical Orthopaedics & Related Research. Mar. 2005;(432):181-7. Not RCT. [pmid: 15738820].
332 Malchau H, Herberts P, Ahnfelt L. Prognosis of total hip replacement in Sweden. Follow-up of 92,675 operations performed 1978–1990. Acta Orthopaedica Scandinavica. Oct. 1993;64(5):497-506. Not RCT. [pmid: 8237312].
333 Malchau H, Wang YX, Karrholm J, et al. Scandinavian multicenter porous coated anatomic total hip arthroplasty study. Clinical and radiographic results with 7- to 10-year follow-up evaluation. Journal of Arthroplasty. Feb. 1997;12(2):133-48. Not RCT. [pmid: 9139095].
334 Malhotra R, Arya R, Bhan S. Bipolar hemiarthroplasty in femoral neck fractures. Archives of Orthopaedic & Trauma Surgery. 1995;114(2):79-82. Not RCT. [pmid: 7734238].
335 Mallory TH, Kraus TJ, Vaughn BK. Intraoperative femoral fractures associated with cementless total hip arthroplasty. Orthopedics. Feb. 1989;12(2):231-9. Not RCT. [pmid: 2922360].
336 March LM, Chamberlain AC, Cameron ID, et al. How best to fix a broken hip. Fractured Neck of Femur Health Outcomes Project Team.[see comment]. Medical Journal of Australia. May. 17. 1999;170(10):489-94. Not RCT. [pmid: 10376027].
337 Mardones RM, Gonzalez C, Chen Q, et al. Surgical treatment of femoroacetabular impingement: evaluation of the effect of the size of the resection. Journal of Bone & Joint Surgery - American Volume. Feb. 2005;87(2):273-9. Not hip fracture.
338 Marhofer P, Faryniak B, Oismuller C, et al. Cardiovascular effects of 6% hetastarch and lactated Ringer's solution during spinal anesthesia.[see comment]. Regional Anesthesia & Pain Medicine. Sep-Oct. 1999;24(5):399-404. Not test of device. [pmid: 10499749].
339 Martyr JW, Clark MX. Hypotension in elderly patients undergoing spinal anaesthesia for repair of fractured neck of femur. A comparison of two different spinal solutions. Anaesthesia & Intensive Care. Oct. 2001;29(5):501-5. Not test of device. [pmid: 11669431].
340 Martyr JW, Stannard KJD, Gillespie G. Spinal-induced hypotension in elderly patients with hip fracture. A comparison of glucose-free bupivacaine with glucose-free bupivacaine and fentanyl. Anaesthesia & Intensive Care. Feb. 2005;33(1):64-8. Not RCT. [pmid: 15957693].
341 Masse A, Bruno A, Bosetti M, et al. Prevention of pin track infection in external fixation with silver coated pins: clinical and microbiological results. Journal of Biomedical Materials Research. Sep. 2000;53(5):600-4. Not hip fracture. [pmid: 10984710].
342 Masson M, Parker MJ, Fleischer S. Internal fixation versus arthroplasty for intracapsular proximal femoral fractures in adults.[update in Cochrane Database Syst Rev. 2006;(4):CD001708; PMID: 17054139]. Cochrane Database of Systematic Reviews. 2003;(2):CD001708. Not RCT. [pmid: 12804413].
343 Matsushita T, Nakamura K, Ohe T, et al. Portable-type stereo fluoroscope for surgery. European Journal of Radiology. Feb. 1998;26(3):312-5. Not hip fracture. [pmid: 9587763].
344 Maurer SG, Wright KE, Kummer FJ, et al. Two or three screws for fixation of femoral neck fractures?. American Journal of Orthopedics. Sep. 2003;32(9):438-42. Not RCT. [pmid: 14560825].
345 Maxwell SL, Lappin KJ, Kealey WD, et al. Arthrodiastasis in Perthes' disease. Preliminary results. Journal of Bone & Joint Surgery - British Volume. Mar. 2004;86(2):244-50. Not hip fracture.
346 Mayman D, Vasarhelyi EM, Long W, et al. Computer-assisted guidewire insertion for hip fracture fixation. Journal of Orthopaedic Trauma. Oct. 2005;19(9):610-5. Not test of device. [pmid: 16247305].
347 Mazda K, Khairouni A, Pennecot GF, et al. Closed flexible intramedullary nailing of the femoral shaft fractures in children. Journal of Pediatric Orthopaedics, Part B. Jul. 1997;6(3):198-202. Not hip fracture. [pmid: 9260649].
348 McClelland B. Perioperative red cell transfusion: evidence, guidelines and practice. Vox Sanguinis. 1998;74(Suppl 2):3-10. Not RCT. [pmid: 9704420].
349 McGrory JE, Trousdale RT, Pagnano MW, et al. Preoperative hip to ankle radiographs in total knee arthroplasty. Clinical Orthopaedics & Related Research. Nov. 2002;(404):196-202. Not hip fracture. [pmid: 12439260].
350 McLaren CA, Buckley JR, Rowley DI. Intertrochanteric fractures of the femur: a randomized prospective trial comparing the Pugh nail with the dynamic hip screw. Injury. May. 1991;22(3):193-6. Not included device. [pmid: 2071200].
351 Meding JB, Ritter MA, Keating EM, et al. A comparison of collared and collarless femoral components in primary cemented total hip arthroplasty: a randomized clinical trial. Journal of Arthroplasty. Feb. 1999;14(2):123-30. Not patient population. [pmid: 10065715].
352 Meislin RJ, Zuckerman JD, Kummer FJ, et al. A biomechanical analysis of the sliding hip screw: the question of plate angle. Journal of Orthopaedic Trauma. 1990;4(2):130-6. Not patient population. [pmid: 2358926].
353 Melhus G, Solberg LB, Dimmen S, et al. Experimental osteoporosis induced by ovariectomy and vitamin D deficiency does not markedly affect fracture healing in rats. Acta Orthopaedica. Jun. 2007;78(3):393-403. Not patient population. [pmid: 17611855].
354 Menezes DFA, Gamulin A, Noesberger B. Is the proximal femoral nail a suitable implant for treatment of all trochanteric fractures?. Clinical Orthopaedics & Related Research. Oct. 2005;439:221-7. Not RCT. [pmid: 16205163].
355 Merrer J, Girou E, Lortat-Jacob A, et al. Surgical site infection after surgery to repair femoral neck fracture: a French multicenter retrospective study. Infection Control & Hospital Epidemiology. Oct. 2007;28(10):1169-74. Not RCT. [pmid: 17828694].
356 Moed BR, Carr SE, Watson JT. Open reduction and internal fixation of posterior wall fractures of the acetabulum. Clinical Orthopaedics & Related Research. Aug. 2000;(377):57-67. Not hip fracture. [pmid: 10943185].
357 Moehring HD, Gravel C, Chapman MW, et al. Comparison of antibiotic beads and intravenous antibiotics in open fractures. Clinical Orthopaedics & Related Research. Mar. 2000;(372):254-61. Not test of device. [pmid: 10738435].
358 Moghari MH, Abolmaesumi P. Global registration of multiple point sets: feasibility and applications in multi-fragment fracture fixation. Medical Image Computing & Computer-Assisted Intervention: MICCAI. 2007;10(Pt 2):943-50. Not RCT. [pmid: 18044659].
359 Monreal M, Lafoz E, Llamazares J, et al. Preoperative platelet count and postoperative blood loss in patients undergoing hip surgery: an inverse correlation. Haemostasis. May-Jun. 1996;26(3):164-9. Not RCT. [pmid: 8738591].
360 Monreal M, Lafoz E, Roca J, et al. Platelet count, antiplatelet therapy and pulmonary embolism--a prospective study in patients with hip surgery. Thrombosis & Haemostasis. Mar. 1995;73(3):380-5. Not test of device. [pmid: 7667819].
361 Mont MA, Seyler TM, Ulrich SD, et al. Effect of changing indications and techniques on total hip resurfacing. Clinical Orthopaedics & Related Research. Dec. 2007;465:63-70. Not RCT. [pmid: 17891034].
362 Morgan M, Black J, Bone F, et al. Clinician-led surgical site infection surveillance of orthopaedic procedures: a UK multi-centre pilot study. Journal of Hospital Infection. Jul. 2005;60(3):201-12. Not test of device. [pmid: 15949611].
363 Morlock MM, Bishop N, Ruther W, et al. Biomechanical, morphological, and histological analysis of early failures in hip resurfacing arthroplasty. Proceedings of the Institution of Mechanical Engineers 2006 Feb; Part H - Journal of Engineering in Medicine. 220(2):333-44. Not RCT.
364 Moroni A, Faldini C, Hoang-Kim A, et al. Alendronate improves screw fixation in osteoporotic bone. Journal of Bone & Joint Surgery - American Volume. Jan. 2007;89(1):96-101. Not test of device.
365 Moroni A, Faldini C, Pegreffi F, et al. Dynamic hip screw compared with external fixation for treatment of osteoporotic pertrochanteric fractures. A prospective, randomized study. Journal of Bone & Joint Surgery - American Volume. Apr. 2005;87(4):753-9. Not included device.
366 Moroni A, Heikkila J, Magyar G, et al. Fixation strength and pin tract infection of hydroxyapatite-coated tapered pins. Clinical Orthopaedics & Related Research. Jul. 2001;(388):209-17. Not patient population. [pmid: 11451122].
367 Moroz LA, Launay F, Kocher MS, et al. Titanium elastic nailing of fractures of the femur in children. Predictors of complications and poor outcome. Journal of Bone & Joint Surgery - British Volume. Oct. 2006;88(10):1361-6. Not hip fracture.
368 Muldoon MP, Padgett DE, Sweet DE, et al. Femoral neck stress fractures and metabolic bone disease. Journal of Orthopaedic Trauma. Mar-Apr. 2001;15(3):181-5. Not RCT. [pmid: 11265008].
369 Mumme T, Muller-Rath R, Andereya S, et al. Uncemented femoral revision arthroplasty using the modular revision prosthesis MRP-TITAN revision stem. Operative Orthopadie und Traumatologie. Mar. 2007;19(1):56-77. Not RCT. [pmid: 17345027].
370 Murnaghan M, McIlmurray L, Mushipe MT, et al. Time for treating bone fracture using rhBMP-2: a randomised placebo controlled mouse fracture trial. Journal of Orthopaedic Research. May. 2005;23(3):625-31. Not hip fracture. [pmid: 15885484].
371 Nau T, Aldrian S, Koenig F, et al. Fixation of femoral fractures in multiple-injury patients with combined chest and head injuries. ANZ Journal of Surgery. Dec. 2003;73(12):1018-21. Not hip fracture. [pmid: 14632896].
372 Neander G, Adolphson P, von Sivers K, et al. Bone and muscle mass after femoral neck fracture. A controlled quantitative computed tomography study of osteosynthesis versus primary total hip arthroplasty. Archives of Orthopaedic & Trauma Surgery. 1997;116(8):470-4. Not RCT - reference group not random. [pmid: 9352040].
373 Nixon M, Taylor G, Sheldon P, et al. Does bone quality predict loosening of cemented total hip replacements?. Journal of Bone & Joint Surgery - British Volume. Oct. 10. 2007;89:1303-8. Not RCT.
374 Noorda RJP, Wuisman PIJM. Mennen plate fixation for the treatment of periprosthetic femoral fractures: a multicenter study of thirty-six fractures.[see comment]. Journal of Bone & Joint Surgery - American Volume. Dec. 2002;84-A(12):2211-5. Not patient population.
375 Nordkild P, Sonne-Holm S, Jensen JS. Femoral neck fracture: sliding screw plate versus sliding nail plate--a randomized trial. Injury. Jul. 1985;16(7):449-54. Not included device. [pmid: 3897051].
376 Norris BL, Patton WC, Rudd JN Jr, et al. Pulmonary dysfunction in patients with femoral shaft fracture treated with intramedullary nailing. Journal of Bone & Joint Surgery - American Volume. Aug. 2001;83-A(8):1162-8. Not hip fracture.
377 Nungu S, Olerud C, Rehnberg L. Treatment of intertrochanteric fractures: comparison of Ender nails and sliding screw plates. Journal of Orthopaedic Trauma. 1991;5(4):452-7. Not included device. [pmid: 1762007].
378 O'Donnell TMP, Murphy DP, Mullett H, et al. Treatment of femoral shaft fractures in children using the "Tobruk" method. American Journal of Orthopedics. Aug. 2006;35(8):356-61. discussion 61. Not patient population. [pmid: 16983865].
379 Oertli D, Hess P, Durig M, et al. Prevention of deep vein thrombosis in patients with hip fractures: low molecular weight heparin versus dextran. World Journal of Surgery. Sep-Oct. 1992;16(5):980-4. discussion 4–5. Not a test of device or US device. [pmid: 1281362].
380 Olsson O. Alternative techniques in trochanteric hip fracture surgery. Clinical and biomechanical studies on the Medoff sliding plate and the Twin hook. Acta Orthopaedica Scandinavica. Supplementum. Oct. 2000;295:1-31. Not RCT. [pmid: 11116961].
381 Oster G, Ollendorf DA, Vera-Llonch M, et al. Economic consequences of venous thromboembolism following major orthopedic surgery. Annals of Pharmacotherapy. Mar. 2004;38(3):377-82. Not RCT. [pmid: 14742829].
382 Ostrum RF, Agarwal A, Lakatos R, et al. Prospective comparison of retrograde and antegrade femoral intramedullary nailing. Journal of Orthopaedic Trauma. Sep-Oct. 2000;14(7):496-501. Not hip fracture. [pmid: 11083612].
383 Owen J, Stephens D, Wright JG. Reliability of hip range of motion using goniometry in pediatric femur shaft fractures. Canadian Journal of Surgery. Aug. 2007;50(4):251-5. Not patient population.
384 Pakos EE, Ioannidis JPA. Radiotherapy vs. nonsteroidal anti-inflammatory drugs for the prevention of heterotopic ossification after major hip procedures: a meta-analysis of randomized trials. International Journal of Radiation Oncology, Biology, Physics. Nov. 1. 2004;60(3):888-95. Not RCT.
385 Palm H, Jacobsen S, Sonne-Holm S, et al. Integrity of the lateral femoral wall in intertrochanteric hip fractures: an important predictor of a reoperation.[see comment]. Journal of Bone & Joint Surgery - American Volume. Mar. 2007;89(3):470-5. Not RCT.
386 Panagiotopoulos EC, Kallivokas AG, Koulioumpas I, et al. Early failure of a zirconia femoral head prosthesis: fracture or fatigue?. Clinical Biomechanics. Aug. 2007;22(7):856-60. Not RCT. [pmid: 17570570].
387 Pape H-C, Grimme K, Van Griensven M, et al. Impact of intramedullary instrumentation versus damage control for femoral fractures on immunoinflammatory parameters: prospective randomized analysis by the EPOFF Study Group. Journal of Trauma-Injury Infection & Critical Care. Jul. 2003;55(1):7-13. Not hip fracture.
388 Pape H-C, Rixen D, Morley J, et al. Impact of the method of initial stabilization for femoral shaft fractures in patients with multiple injuries at risk for complications (borderline patients). Annals of Surgery. Sep. 2007;246(3):491-9. discussion 9–501. Not patient population. [pmid: 17717453].
389 Park Y-S, Hwang S-K, Choy W-S, et al. Ceramic failure after total hip arthroplasty with an alumina-on- alumina bearing.[see comment]. Journal of Bone & Joint Surgery - American Volume. Apr. 2006;88(4):780-7. Not RCT.
390 Parker MJ. RAB-plate vs Richards CHS plate for unstable trochanteric hip fractures--a randomized study of 233 patients with 1-year follow-up.[comment]. Acta Orthopaedica Scandinavica. Feb. 1999;70(1):101-2. Not hip fracture. [pmid: 10191762].
391 Parker MJ, Banajee A. Surgical approaches and ancillary techniques for internal fixation of intracapsular proximal femoral fractures.[update of Cochrane Database Syst Rev. 2000;(3):CD001705; PMID: 10908508]. Cochrane Database of Systematic Reviews. 2005;(2):CD001705. Not RCT. [pmid: 15846622].
392 Parker MJ, Dynan Y. Surgical approaches and ancillary techniques for internal fixation of intracapsular proximal femoral fractures.[update in Cochrane Database Syst Rev. 2005;(2):CD001705; PMID: 15846622]. Cochrane Database of Systematic Reviews. 2000;(3):CD001705. Duplicate. [pmid: 10908508].
393 Parker MJ, Gurusamy K. Arthroplasties (with and without bone cement) for proximal femoral fractures in adults.[update in Cochrane Database Syst Rev. 2006;3:CD001706; PMID: 16855974][update of Cochrane Database Syst Rev. 2001;(3):CD001706; PMID: 11686994]. Cochrane Database of Systematic Reviews. 2004;(2):CD001706. Duplicate. [pmid: 15106159].
394 Parker MJ, Gurusamy K. Internal fixation versus arthroplasty for intracapsular proximal femoral fractures in adults.[update of Cochrane Database Syst Rev. 2003;(2):CD001708; PMID: 12804413]. Cochrane Database of Systematic Reviews. 2006;(4):CD001708. Not RCT. [pmid: 17054139].
395 Parker MJ, Gurusamy K. Arthroplasties (with and without bone cement) for proximal femoral fractures in adults.[update of Cochrane Database Syst Rev. 2004;(2):CD001706; PMID: 15106159]. Cochrane Database of Systematic Reviews. 2006;3:CD001706. Not RCT. [pmid: 16855974].
396 Parker MJ, Handoll HH. Conservative versus operative treatment for extracapsular hip fractures.[update in Cochrane Database Syst Rev. 2000;(4):CD000337; PMID: 11034683]. Cochrane Database of Systematic Reviews. 2000;(2):CD000337. Not RCT.
397 Parker MJ, Handoll HH. Gamma and other cephalocondylic intramedullary nails versus extramedullary implants for extracapsular hip fractures.[update in Cochrane Database Syst Rev. 2002;(1):CD000093; PMID: 11869563]. Cochrane Database of Systematic Reviews. 2000;(2):CD000093. Duplicate. [pmid: 10796296].
398 Parker MJ, Handoll HH. Replacement arthroplasty versus internal fixation for extracapsular hip fractures.[update in Cochrane Database Syst Rev. 2006;(2):CD000086; PMID: 16625528]. Cochrane Database of Systematic Reviews. 2000;(2):CD000086. Duplicate. [pmid: 10796293].
399 Parker MJ, Handoll HH. Extramedullary fixation implants and external fixators for extracapsular hip fractures.[update in Cochrane Database Syst Rev. 2006;(1):CD000339; PMID: 16437422][update of Cochrane Database Syst Rev. 2002;(2):CD000339; PMID: 12076392]. Cochrane Database of Systematic Reviews. 2002;(4):CD000339. Duplicate.
400 Parker MJ, Handoll HH. Gamma and other cephalocondylic intramedullary nails versus extramedullary implants for extracapsular hip fractures.[update in Cochrane Database Syst Rev. 2004;(1):CD000093; PMID: 14973946][update of Cochrane Database Syst Rev. 2002;(1):CD000093; PMID: 11869563]. Cochrane Database of Systematic Reviews. 2002;(4):CD000093. Duplicate.
401 Parker MJ, Handoll HH. Extramedullary fixation implants for extracapsular hip fractures.[update in Cochrane Database Syst Rev. 2002;(4):CD000339; PMID: 12519541][update of Cochrane Database Syst Rev. 2001;(2):CD000339; PMID: 11405960]. Cochrane Database of Systematic Reviews. 2002;(2):CD000339. Not RCT.
402 Parker MJ, Handoll HH. Gamma and other cephalocondylic intramedullary nails versus extramedullary implants for extracapsular hip fractures.[update in Cochrane Database Syst Rev. 2002;(4):CD000093; PMID: 12519535][update of Cochrane Database Syst Rev. 2000;(2):CD000093; PMID: 10796296]. Cochrane Database of Systematic Reviews. 2002;(1):CD000093. Duplicate.
403 Parker MJ, Handoll HH, Bhargara A. Conservative versus operative treatment for hip fractures.[update of Cochrane Database Syst Rev. 2000;(2):CD000337; PMID: 10796345]. Cochrane Database of Systematic Reviews. 2000;(4):CD000337. Not RCT.
404 Parker MJ, Handoll HH, Bhonsle S, et al. Condylocephalic nails versus extramedullary implants for extracapsular hip fractures. Cochrane Database of Systematic Reviews. 2000;(2):CD000338. Not RCT. [pmid: 10796346].
405 Parker MJ, Handoll HH, Chinoy MA. Extramedullary fixation implants for extracapsular hip fractures.[update in Cochrane Database Syst Rev. 2001;(2):CD000339; PMID: 11405960][update of Cochrane Database Syst Rev. 2000;(2):CD000339; PMID: 10796347]. Cochrane Database of Systematic Reviews. 2000;(3):CD000339. Duplicate.
406 Parker MJ, Handoll HH, Chinoy MA. Extramedullary fixation implants for extracapsular hip fractures.[update in Cochrane Database Syst Rev. 2000;(3):CD000339; PMID: 10908472]. Cochrane Database of Systematic Reviews. 2000;(2):CD000339. Duplicate.
407 Parker MJ, Handoll HH, Chinoy MA. Extramedullary fixation implants for extracapsular hip fractures.[update in Cochrane Database Syst Rev. 2002;(2):CD000339; PMID: 12076392][update of Cochrane Database Syst Rev. 2000;(3):CD000339; PMID: 10908472]. Cochrane Database of Systematic Reviews. 2001;(2):CD000339. Duplicate. [pmid: 11405960].
408 Parker MJ, Handoll HH, Dynan Y. Mobilisation strategies after hip fracture surgery in adults.[update in Cochrane Database Syst Rev. 2002;(2):CD001704; PMID: 12076418]. Cochrane Database of Systematic Reviews. 2000;(3):CD001704. Duplicate. [pmid: 10908507].
409 Parker MJ, Handoll HH, Dynan Y. Mobilisation strategies after hip fracture surgery in adults.[update in Cochrane Database Syst Rev. 2003;(1):CD001704; PMID: 12535411][update of Cochrane Database Syst Rev. 2000;(3):CD001704; PMID: 10908507]. Cochrane Database of Systematic Reviews. 2002;(2):CD001704. Not RCT. [pmid: 12076418].
410 Parker MJ, Handoll HHG. Gamma and other cephalocondylic intramedullary nails versus extramedullary implants for extracapsular hip fractures.[update in Cochrane Database Syst Rev. 2005;(4):CD000093; PMID: 16235272][update of Cochrane Database Syst Rev. 2002;(4):CD000093; PMID: 12519535]. Cochrane Database of Systematic Reviews. 2004;(1):CD000093. Not RCT. [pmid: 14973946].
411 Parker MJ, Handoll HHG. Gamma and other cephalocondylic intramedullary nails versus extramedullary implants for extracapsular hip fractures in adults.[update of Cochrane Database Syst Rev. 2004;(1):CD000093; PMID: 14973946]. Cochrane Database of Systematic Reviews. 2005;(4):CD000093. Duplicate. [pmid: 16235272].
412 Parker MJ, Handoll HHG. Intramedullary nails for extracapsular hip fractures in adults.[update in Cochrane Database Syst Rev. 2006;3:CD004961; PMID: 16856070]. Cochrane Database of Systematic Reviews. 2005;(2):CD004961. Duplicate. [pmid: 15846737].
413 Parker MJ, Handoll HHG. Intramedullary nails for extracapsular hip fractures in adults.[update of Cochrane Database Syst Rev. 2005;(2):CD004961; PMID: 15846737]. Cochrane Database of Systematic Reviews. 2006;3:CD004961. Not RCT. [pmid: 16856070].
414 Parker MJ, Handoll HHG. Replacement arthroplasty versus internal fixation for extracapsular hip fractures in adults.[update of Cochrane Database Syst Rev. 2000;(2):CD000086; PMID: 10796293]. Cochrane Database of Systematic Reviews. 2006;(2):CD000086. Not RCT. [pmid: 16625528].
415 Parker MJ, Handoll HHG. Extramedullary fixation implants and external fixators for extracapsular hip fractures in adults.[update of Cochrane Database Syst Rev. 2002;(4):CD000339; PMID: 12519541]. Cochrane Database of Systematic Reviews. 2006;(1):CD000339. Not RCT. [pmid: 16437422].
416 Parker MJ, Livingstone V, Clifton R, et al. Closed suction surgical wound drainage after orthopaedic surgery.[update of Cochrane Database Syst Rev. 2001;(4):CD001825; PMID: 11687125]. Cochrane Database of Systematic Reviews. 2007;(3):CD001825. Not RCT. [pmid: 17636687].
417 Parker MJ, Pryor GA. Gamma versus DHS nailing for extracapsular femoral fractures. Meta-analysis of ten randomised trials. International Orthopaedics. 1996;20(3):163-8. Not RCT. [pmid: 8832319].
418 Parker MJ, Raghavan R, Gurusamy K. Incidence of fracture-healing complications after femoral neck fractures. Clinical Orthopaedics & Related Research. May. 2007;458:175-9. Not RCT. [pmid: 17224836].
419 Parker MJ, Rajan D. Arthroplasties (with and without bone cement) for proximal femoral fractures in adults.[update in Cochrane Database Syst Rev. 2004;(2):CD001706; PMID: 15106159]. Cochrane Database of Systematic Reviews. 2001;(3):CD001706. Duplicate. [pmid: 11686994].
420 Parker MJ, Roberts C. Closed suction surgical wound drainage after orthopaedic surgery.[update in Cochrane Database Syst Rev. 2007;(3):CD001825; PMID: 17636687]. Cochrane Database of Systematic Reviews. 2001;(4):CD001825. Duplicate. [pmid: 11687125].
421 Parker MJ, Stockton G. Internal fixation implants for intracapsular proximal femoral fractures in adults. Cochrane Database of Systematic Reviews. 2001;(4):CD001467. Not RCT. [pmid: 11687113].
422 Parker MJ, Tripuraneni G, McGreggor-Riley J. Osteotomy, compression and reaming techniques for internal fixation of extracapsular hip fractures.[update in Cochrane Database Syst Rev. 2001;(3):CD000522; PMID: 11686964]. Cochrane Database of Systematic Reviews. 2000;(2):CD000522. Duplicate. [pmid: 10796388].
423 Parker MJ, Tripuraneni G, McGreggor-Riley J. Osteotomy, compression and reaming techniques for internal fixation of extracapsular hip fractures.[update of Cochrane Database Syst Rev. 2000;(2):CD000522; PMID: 10796388]. Cochrane Database of Systematic Reviews. 2001;(3):CD000522. Not RCT. [pmid: 11686964].
424 Partio EK, Tuompo P, Hirvensalo E, et al. Totally absorbable fixation in the treatment of fractures of the distal femoral epiphyses. A prospective clinical study. Archives of Orthopaedic & Trauma Surgery. 1997;116(4):213-6. Not hip fracture. [pmid: 9128774].
425 Patel AA, Ricci WM, McDonald DJ, et al. Treatment of periprosthetic femoral shaft nonunion. Journal of Arthroplasty. Apr. 2006;21(3):435-42. Not hip fracture. [pmid: 16627155].
426 Pedersen A, Johnsen S, Overgaard S, et al. Registration in the danish hip arthroplasty registry: completeness of total hip arthroplasties and positive predictive value of registered diagnosis and postoperative complications. Acta Orthopaedica Scandinavica. Aug. 2004;75(4):434-41. Not RCT. [pmid: 15370588].
427 Pedersen PU. Nutritional care: the effectiveness of actively involving older patients.[see comment]. Journal of Clinical Nursing. Feb. 2005;14(2):247-55. Not test of device. [pmid: 15669934].
428 Peichl P, Griesmacher A, Kumpan W, et al. Clinical outcome of salmon calcitonin nasal spray treatment in postmenopausal women after total hip arthroplasty. Gerontology. Jul-Aug. 2005;51(4):242-52. Not test of device. [pmid: 15980653].
429 Peichl P, Marteau R, Griesmacher A, et al. Salmon calcitonin nasal spray treatment for postmenopausal women after hip fracture with total hip arthroplasty. Journal of Bone & Mineral Metabolism. 2005;23(3):243-52. Not test of device. [pmid: 15838628].
430 Persson P-E, Nilsson OS, Berggren A-M. Do non-steroidal anti-inflammatory drugs cause endoprosthetic loosening? A 10-year follow-up of a randomized trial on ibuprofen for prevention of heterotopic ossification after hip arthroplasty.[see comment]. Acta Orthopaedica. Dec. 2005;76(6):735-40. Not test of device. [pmid: 16470423].
431 Peskun C, McKee M, Kreder H, et al. Functional outcome of ipsilateral intertrochanteric and femoral shaft fractures. Journal of Orthopaedic Trauma. Feb. 2008;22(2):102-6. Not RCT. [pmid: 18349777].
432 Peyser A, Weil Y, Liebergall M, et al. Percutaneous compression plating for intertrochanteric fractures. Surgical technique, tips for surgery, and results. Operative Orthopadie und Traumatologie. Jun. 2005;17(2):158-77. Not RCT. [pmid: 16007384].
433 Pitsaer E, Samuel AW. Functional outcome after intertrochanteric fractures of the femur: does the implant matter? A prospective study of 100 consecutive cases. Injury. 1993;24(1):35-6. Not included device. [pmid: 8432572].
434 Pitto RP, Blunk J, Kossler M. Transesophageal echocardiography and clinical features of fat embolism during cemented total hip arthroplasty. A randomized study in patients with a femoral neck fracture. Archives of Orthopaedic & Trauma Surgery. 2000;120(1–2):53-8. Other exclusion. [pmid: 10653105].
435 Prandoni P, Sabbion P, Tanduo C, et al. Prevention of venous thromboembolism in high-risk surgical and medical patients. Seminars in Vascular Medicine. 2001;1(1):61-70. Not RCT. [pmid: 15199515].
436 Prayson MJ, Datta DK, Marshall MP. Mechanical comparison of endosteal substitution and lateral plate fixation in supracondylar fractures of the femur. Journal of Orthopaedic Trauma. Feb. 2001;15(2):96-100. Not hip fracture. [pmid: 11232661].
437 Prokop A, Helling H-J, Hahn U, et al. Biodegradable implants for Pipkin fractures. Clinical Orthopaedics & Related Research. Mar. 2005;(432):226-33. Not RCT. [pmid: 15738826].
438 Putz P, Buyse H, Delvaux D, et al. Triflusal versus acetylsalicylic acid: a double-blind study for the prophylaxis of deep vein thrombosis after hip surgery. Acta Chirurgica Belgica. Nov-Dec. 1991;91(6):269-76. Not a test of device or US device. [pmid: 1781229].
439 Qidwai SA, Khattak ZK. Treatment of femoral shaft fractures in children by intramedullary Kirschner wires. Journal of Trauma-Injury Infection & Critical Care. Feb. 2000;48(2):256-9. Not hip fracture.
440 Quintana JM, Azkarate J, Goenaga JI, et al. Evaluation of the appropriateness of hip joint replacement techniques. International Journal of Technology Assessment in Health Care. 2000;16(1):165-77. Not RCT. [pmid: 10815362].
441 Raaymakers ELFB, Marti RK, et al. Concerning Tero Heikkinen. Hemiarthroplasty or osteosynthesis in cervical hip fractures: matched-pair analysis in 892 patients.[comment]. Archives of Orthopaedic & Trauma Surgery. 2003. Apr. 2002;123(2–3):134. author reply 5. Not RCT. [pmid: 12721696].
442 Randelli P, Landi S, Fanton F, et al. Treatment of ipsilateral femoral neck and shaft fractures with the Russell-Taylor reconstructive nail. Orthopedics. Jul. 1999;22(7):673-6. Not RCT. [pmid: 10418862].
443 Ravenscroft MJ, Harker J, Buch KA. A prospective, randomised, controlled trial comparing wound dressings used in hip and knee surgery: Aquacel and Tegaderm versus Cutiplast. Annals of the Royal College of Surgeons of England. Jan. 2006;88(1):18-22. Not test of device. [pmid: 16460632].
444 Rebuzzi E, Pannone A, Schiavetti S, et al. IMHS clinical experience in the treatment of peritrochanteric fractures. The results of a multicentric Italian study of 981 cases. Injury. Jun. 2002;33(5):407-12. Not RCT. [pmid: 12095720].
445 Reindl R, Steffen T, Cohen L, et al. Elective lumbar spinal decompression in the elderly: is it a high-risk operation?. Canadian Journal of Surgery. Feb. 2003;46(1):43-6. Not hip fracture.
446 Reynders P, Broos PL. Unreamed intramedullary nailing of femoral shaft fractures using a traction device. Injury. Jan. 1998;29(1):81-4. Not hip fracture. [pmid: 9659490].
447 Ricci WM, Devinney S, Haidukewych G, et al. Trochanteric nail insertion for the treatment of femoral shaft fractures. Journal of Orthopaedic Trauma. Sep. 2005;19(8):511-7. Not hip fracture. [pmid: 16118557].
448 Ricci WM, Schwappach J, Tucker M, et al. Trochanteric versus piriformis entry portal for the treatment of femoral shaft fractures. Journal of Orthopaedic Trauma. Nov-Dec. 2006;20(10):663-7. Not RCT. [pmid: 17106375].
449 Robinson AH, Moiz M, Hallett JP. Use of a laser guide to reduce screening time for the dynamic hip screw. Injury. Dec. 1996;27(10):713-4. Not test of device. [pmid: 9135750].
450 Rodgers A. The appropriate roles of audit and randomisation in determining the efficacy of anaesthetic interventions. Anaesthesia. Jan. 1995;50(1):89-90. Not hip fracture. [pmid: 7702165].
451 Rogmark C, Johnell O. Orthopaedic treatment of displaced femoral neck fractures in elderly patients. Disability & Rehabilitation. Sep 30-Oct 15. 2005;27(18–19):1143-9. Not RCT. [pmid: 16278183].
452 Rogmark C, Johnell O. Primary arthroplasty is better than internal fixation of displaced femoral neck fractures: a meta-analysis of 14 randomized studies with 2,289 patients.[see comment]. Acta Orthopaedica. Jun. 2006;77(3):359-67. Not RCT. [pmid: 16819672].
453 Rompe JD, Rosendahl T, Schollner C, et al. High-energy extracorporeal shock wave treatment of nonunions. Clinical Orthopaedics & Related Research. Jun. 2001;(387):102-11. Not hip fracture. [pmid: 11400870].
454 Rosen JE, Chen FS, Hiebert R, et al. Efficacy of preoperative skin traction in hip fracture patients: a prospective, randomized study.[see comment]. Journal of Orthopaedic Trauma. Feb. 2001;15(2):81-5. Not test of device. [pmid: 11232658].
455 Roth SE, Rebello MM, Kreder H, et al. Pressurization of the metastatic femur during prophylactic intramedullary nail fixation. Journal of Trauma-Injury Infection & Critical Care. Aug. 2004;57(2):333-9. Not hip fracture.
456 Rouleau JP, Blasier RB, Tsai E, et al. Cannulated hip screws: a study of fixation integrity, cut-out resistance, and high-cycle bending fatigue performance. Journal of Orthopaedic Trauma. Aug. 1994;8(4):293-9. Other exclusion - cadaver. [pmid: 7965290].
457 Saarenpaa I, Heikkinen T, Jalovaara P. Treatment of subtrochanteric fractures. A comparison of the Gamma nail and the dynamic hip screw: short-term outcome in 58 patients. International Orthopaedics. Feb. 2007;31(1):65-70. Not RCT. [pmid: 16633810].
458 Sakamoto K, Nakamura T, Hagino H, et al. Report on the Japanese Orthopaedic Association's 3-year project observing hip fractures at fixed-point hospitals. Journal of Orthopaedic Science. Mar. 2006;11(2):127-34. Not RCT. [pmid: 16568383].
459 Sandby-Thomas M, Sullivan G, Hall JE. A national survey into the peri-operative anaesthetic management of patients presenting for surgical correction of a fractured neck of femur. Anaesthesia. Mar. 2008;63(3):250-8. Not RCT. [pmid: 18289230].
460 Sato Y, Kanoko T, Yasuda H, et al. Beneficial effect of etidronate therapy in immobilized hip fracture patients. American Journal of Physical Medicine & Rehabilitation. Apr. 2004;83(4):298-303. Not test of device. [pmid: 15024332].
461 Scalea TM, Boswell SA, Scott JD, et al. External fixation as a bridge to intramedullary nailing for patients with multiple injuries and with femur fractures: damage control orthopedics. Journal of Trauma-Injury Infection & Critical Care. Apr. 2000;48(4):613-21. discussion 21–3. Not hip fracture.
462 Schiff RL, Kahn SR, Shrier I, et al. Identifying orthopedic patients at high risk for venous thromboembolism despite thromboprophylaxis. Chest. Nov. 2005;128(5):3364-71. Not test of device. [pmid: 16304285].
463 Schipper IB, Marti RK, van der Werken C. Unstable trochanteric femoral fractures: extramedullary or intramedullary fixation. Review of literature. Injury. Feb. 2004;35(2):142-51. Not RCT. [pmid: 14736471].
464 Schlag G, Gaudernak T, Pelinka H, et al. Thromboembolic prophylaxis in hip fracture. Acta Orthopaedica Scandinavica. Aug. 1986;57(4):340-3. Not test of device. [pmid: 3788500].
465 Schutz M, Buhler M, Swiontkowski M, et al. Documentation. Injury. 1994;25(Suppl 3):S-C34-7. Not hip fracture.
466 Schutz M, Muller M, Krettek C, et al. Minimally invasive fracture stabilization of distal femoral fractures with the LISS: a prospective multicenter study. Results of a clinical study with special emphasis on difficult cases. Injury. Dec. 2001;32(Suppl 3):SC48-54. Not hip fracture. [pmid: 11888194].
467 Schutz M, Muller M, Regazzoni P, et al. Use of the less invasive stabilization system (LISS) in patients with distal femoral (AO33) fractures: a prospective multicenter study. Archives of Orthopaedic & Trauma Surgery. Mar. 2005;125(2):102-8. Not hip fracture. [pmid: 15688230].
468 Seeman E. Unresolved issues in osteoporosis in men. Reviews in Endocrine & Metabolic Disorders. Jan. 2001;2(1):45-64. Not RCT. [pmid: 11704979].
469 Selvakumar K, Saw KY, Fathima M. Comparison study between reamed and unreamed nailing of closed femoral fractures. Medical Journal of Malaysia. Dec. 2001;56(Suppl D):24-8. Not hip fracture. [pmid: 14569762].
470 Seral F, Villar JM, Esteller A, et al. Five-year follow-up evaluation of the noncemented press-fit titanium hip-joint endoprosthesis. Clinical Orthopaedics & Related Research. Oct. 1992;(283):49-56. Not RCT. [pmid: 1395270].
471 Sernbo I, Holmquist H, Redlund-Johnell I, et al. Radiographic prediction of failure after fixation of cervical hip fracture. Acta Orthopaedica Scandinavica. Jun. 1994;65(3):295-8. Not RCT - comparison groups not randomized. [pmid: 8042481].
472 Sernbo I, Johnell O, Baath L, et al. Internal fixation of 410 cervical hip fractures. A randomized comparison of a single nail versus two hook-pins. Acta Orthopaedica Scandinavica. Oct. 1990;61(5):411-4. Not included device. [pmid: 2239163].
473 Sernbo I, Johnell O, Gentz CF, et al. Unstable intertrochanteric fractures of the hip. Treatment with Ender pins compared with a compression hip-screw. Journal of Bone & Joint Surgery - American Volume. Oct. 1988;70(9):1297-303. Not included device.
474 Shawen SB, Belmont PJ Jr, Klemme WR, et al. Osteoporosis and anterior femoral notching in periprosthetic supracondylar femoral fractures: a biomechanical analysis. Journal of Bone & Joint Surgery - American Volume. Jan. 2003;85-A(1):115-21. Not hip fracture.
475 Shepherd LE, Shean CJ, Gelalis ID, et al. Prospective randomized study of reamed versus unreamed femoral intramedullary nailing: an assessment of procedures.[see comment]. Journal of Orthopaedic Trauma. Jan. 2001;15(1):28-32. discussion -3. Not hip fracture. [pmid: 11147684].
476 Shimmin AJ, Back D. Femoral neck fractures following Birmingham hip resurfacing: a national review of 50 cases.[see comment]. Journal of Bone & Joint Surgery - British Volume. Apr. 2005;87(4):463-4. Not patient population.
477 Siebel T, Maubach S, Morlock MM. Lessons learned from early clinical experience and results of 300 ASR hip resurfacing implantations. Proceedings of the Institution of Mechanical Engineers 2006 Feb; Part H - Journal of Engineering in Medicine. 220(2):345-53. Not RCT.
478 Siebenrock KA, Gautier E, Woo AKH, et al. Surgical dislocation of the femoral head for joint debridement and accurate reduction of fractures of the acetabulum. Journal of Orthopaedic Trauma. Sep. 2002;16(8):543-52. Not hip fracture. [pmid: 12352562].
479 Simmermacher RK, Bosch AM, Van der Werken C. The AO/ASIF-proximal femoral nail (PFN): a new device for the treatment of unstable proximal femoral fractures. Injury. Jun. 1999;30(5):327-32. Not RCT. [pmid: 10505125].
480 Singh GK, Deshmukh RG. Uncemented Austin-Moore and cemented Thompson unipolar hemiarthroplasty for displaced fracture neck of femur--comparison of complications and patient satisfaction.[see comment]. Injury. Feb. 2006;37(2):169-74. Not RCT. [pmid: 16413024].
481 Slonim AD, Marcin JP, Turenne W, et al. Pediatric patient safety events during hospitalization: approaches to accounting for institution-level effects. Health Services Research. Dec. 2007;42(6 Pt 1):2275-93. discussion 94–323. Not patient population. [pmid: 17995566].
482 Smith MD, Cody DD, Goldstein SA, et al. Proximal femoral bone density and its correlation to fracture load and hip-screw penetration load. Clinical Orthopaedics & Related Research. Oct. 1992;(283):244-51. Not patient population. [pmid: 1395253].
483 Smith RM, Giannoudis PV, Bellamy MC, et al. Interleukin-10 release and monocyte human leukocyte antigen-DR expression during femoral nailing. Clinical Orthopaedics & Related Research. Apr. 2000;(373):233-40. Not hip fracture. [pmid: 10810482].
484 Smith WR, Ziran B, Agudelo JF, et al. Expandable intramedullary nailing for tibial and femoral fractures: a preliminary analysis of perioperative complications. Journal of Orthopaedic Trauma. May. 2006;20(5):310-4. discussion 5–6. Not hip fracture. [pmid: 16766932].
485 Sochart DH. Poor results following internal fixation of displaced subcapital femoral fractures: complacency in fracture reduction. Archives of Orthopaedic & Trauma Surgery. 1998;117(6–7):379-82. Not RCT. [pmid: 9709856].
486 Sonne-Holm S, Nordkild P, Dyrbye M, et al. The predictive value of bone scintigraphy after internal fixation of femoral neck fractures. Injury. Jan. 1987;18(1):33-5. Not test of device. [pmid: 3440612].
487 Sorensen JL, Varmarken JE, Bomler J. Internal fixation of femoral neck fractures. Dynamic Hip and Gouffon screws compared in 73 patients. Acta Orthopaedica Scandinavica. Jun. 1992;63(3):288-92. Not included device. [pmid: 1609592].
488 Sors H, Meyer G. Place of aspirin in prophylaxis of venous thromboembolism.[comment]. Lancet. Apr. 15. 2000;355(9212):1288-9. Not hip fracture. [pmid: 10776735].
489 Southwell-Keely JP, Russo RR, March L, et al. Antibiotic prophylaxis in hip fracture surgery: a metaanalysis. Clinical Orthopaedics & Related Research. Feb. 2004;(419):179-84. Not RCT. [pmid: 15021151].
490 Springer BD, Sim FH, Hanssen AD, et al. The modular segmental kinematic rotating hinge for nonneoplastic limb salvage. Clinical Orthopaedics & Related Research. Apr. 2004;(421):181-7. Not hip fracture. [pmid: 15123945].
491 Squires B, Bannister G. Displaced intracapsular neck of femur fractures in mobile independent patients: total hip replacement or hemiarthroplasty?. Injury. Jun. 1999;30(5):345-8. Not RCT. [pmid: 10505129].
492 Stankewich CJ, Swiontkowski MF, Tencer AF, et al. Augmentation of femoral neck fracture fixation with an injectable calcium-phosphate bone mineral cement. Journal of Orthopaedic Research. Sep. 1996;14(5):786-93. Not RCT. [pmid: 8893773].
493 Stankovski V, Bratko I, Demsar J, et al. Induction of hypotheses concerning hip arthroplasty: a modified methodology for medical research. Methods of Information in Medicine. 2001;40(5):392-6. Not RCT. [pmid: 11776737].
494 Stannard JP, Harris HW, Volgas DA, et al. Functional outcome of patients with femoral head fractures associated with hip dislocations. Clinical Orthopaedics & Related Research. Aug. 2000;(377):44-56. Not hip fracture. [pmid: 10943184].
495 Stark A, Brostrom LA, Barrios C, et al. A prospective randomized study of the use of sliding hip screws and Ender nails for trochanteric fractures of the femur. International Orthopaedics. 1992;16(4):359-62. Not included device. [pmid: 1473889].
496 Starr AJ, Hay MT, Reinert CM, et al. Cephalomedullary nails in the treatment of high-energy proximal femur fractures in young patients: a prospective, randomized comparison of trochanteric versus piriformis fossa entry portal. Journal of Orthopaedic Trauma. Apr. 2006;20(4):240-6. Not patient population. [pmid: 16721238].
497 Stephen DJG, Kreder HJ, Schemitsch EH, et al. Femoral intramedullary nailing: comparison of fracture-table and manual traction. a prospective, randomized study. Journal of Bone & Joint Surgery - American Volume. Sep. 2002;84-A(9):1514-21. Not hip fracture.
498 Stranks GJ, MacKenzie NA, Grover ML, et al. The AV Impulse System reduces deep-vein thrombosis and swelling after hemiarthroplasty for hip fracture. Journal of Bone & Joint Surgery - British Volume. Sep. 1992;74(5):775-8. Not test of device.
499 Strecker W, Gonschorek O, Fleischmann W, et al. Thromboxane--co-factor of pulmonary disturbances in intramedullary nailing. Injury. 1993;24(Suppl 3):S68-72. Not hip fracture. [pmid: 8168879].
500 Stromberg L, Ohlen G, Nordin C, et al. Postoperative mental impairment in hip fracture patients. A randomized study of reorientation measures in 223 patients. Acta Orthopaedica Scandinavica. Jun. 1999;70(3):250-5. Not test of device. [pmid: 10429599].
501 Strycker ML. Biodegradable internal fixation. Journal of Foot & Ankle Surgery. Jan-Feb. 1995;34(1):82-8. Not hip fracture. [pmid: 7780399].
502 Suhm N, Messmer P, Zuna I, et al. Fluoroscopic guidance versus surgical navigation for distal locking of intramedullary implants. A prospective, controlled clinical study. Injury. Jun. 2004;35(6):567-74. Not test of device. [pmid: 15135275].
503 Svartling N, Lehtinen AM, Tarkkanen L. The effect of anaesthesia on changes in blood pressure and plasma cortisol levels induced by cementation with methylmethacrylate. Acta Anaesthesiologica Scandinavica. Apr. 1986;30(3):247-52. Not test of device. [pmid: 3739582].
504 Swiontkowski MF. Criteria for bone debridement in massive lower limb trauma. Clinical Orthopaedics & Related Research. Jun. 1989;(243):41-7. Not RCT. [pmid: 2656032].
505 Taberner DA, Poller L, Thomson JM, et al. Randomized study of adjusted versus fixed low dose heparin prophylaxis of deep vein thrombosis in hip surgery. British Journal of Surgery. Sep. 1989;76(9):933-5. Not test of device. [pmid: 2804589].
506 Taeger G, Ruchholtz S, Waydhas C, et al. Damage control orthopedics in patients with multiple injuries is effective, time saving, and safe. Journal of Trauma- Injury Infection & Critical Care. Aug. 2005;59(2):409-16. discussion 17. Not patient population.
507 Takeshita K, Lenke LG, Bridwell KH, et al. Analysis of patients with nonambulatory neuromuscular scoliosis surgically treated to the pelvis with intraoperative halo-femoral traction. Spine. Sep. 15. 2006;31(20):2381-5. Not hip fracture. [pmid: 16985468].
508 Tan V, Pepe MD, Glaser DL, et al. Well-leg compartment pressures during hemilithotomy position for fracture fixation. Journal of Orthopaedic Trauma. Mar-Apr. 2000;14(3):157-61. Not patient population. [pmid: 10791664].
509 Tappen RM, Whitehead D, Folden SL, et al. Effect of a video intervention on functional recovery following hip replacement and hip fracture repair. Rehabilitation Nursing. Sep-Oct. 2003;28(5):148-53. Not RCT. [pmid: 14521003].
510 Taylor RH, Joskowicz L, Williamson B, et al. Computer-integrated revision total hip replacement surgery: concept and preliminary results. Medical Image Analysis. Sep. 1999;3(3):301-19. Not hip fracture. [pmid: 10710298].
511 Thomas DP. PEP trial. Pulmonary Embolism Prevention. Lancet. Jul. 15. 2000;356(9225):249-50. author reply 50–1. Not hip fracture. [pmid: 10963222].
512 Tidermark J. Quality of life and femoral neck fractures. Acta Orthopaedica Scandinavica. Apr. 2003;Supplementum 74(309):1-42. Duplicate. [pmid: 12811943].
513 Tidermark J, Bergstrom G, Svensson O, et al. Responsiveness of the EuroQol (EQ 5-D) and the SF-36 in elderly patients with displaced femoral neck fractures. Quality of Life Research. Dec. 2003;12(8):1069-79. Not RCT. [pmid: 14651424].
514 Tidermark J, Ponzer S, Carlsson P, et al. Effects of protein-rich supplementation and nandrolone in lean elderly women with femoral neck fractures. Clinical Nutrition. Aug. 2004;23(4):587-96. Not test of device. [pmid: 15297095].
515 Tidermark J, Zethraeus N, Svensson O, et al. Quality of life related to fracture displacement among elderly patients with femoral neck fractures treated with internal fixation. Journal of Orthopaedic Trauma. Jan. 2002;16(1):34-8. Not RCT. [pmid: 11782631].
516 Tornetta P 3rd, Tiburzi D. The treatment of femoral shaft fractures using intramedullary interlocked nails with and without intramedullary reaming: a preliminary report. Journal of Orthopaedic Trauma. Feb-Mar. 1997;11(2):89-92. Not hip fracture. [pmid: 9057141].
517 Tornetta P 3rd, Tiburzi D. Antegrade or retrograde reamed femoral nailing. A prospective, randomised trial. Journal of Bone & Joint Surgery - British Volume. Jul. 2000;82(5):652-4. Not hip fracture.
518 Tornetta P 3rd, Tiburzi D. Reamed versus nonreamed anterograde femoral nailing. Journal of Orthopaedic Trauma. Jan. 2000;14(1):15-9. Not patient population. [pmid: 10630797].
519 Tsai M-D, Hsieh M-S, Tsai C-H. Bone drilling haptic interaction for orthopedic surgical simulator. Computers in Biology & Medicine. Dec. 2007;37(12):1709-18. Not patient population. [pmid: 17568576].
520 Tsakalakos N, Magiasis B, Tsekoura M, et al. The effect of short-term calcitonin administration on biochemical bone markers in patients with acute immobilization following hip fracture. Osteoporosis International. Dec. 1993;3(6):337-40. Not a test of device or US device. [pmid: 8292845].
521 Tucker MC, Schwappach JR, Leighton RK, et al. Results of femoral intramedullary nailing in patients who are obese versus those who are not obese: a prospective multicenter comparison study. Journal of Orthopaedic Trauma. Sep. 2007;21(8):523-9. Not hip fracture. [pmid: 17805018].
522 Turker G, Uckunkaya N, Yavascaoglu B, et al. Comparison of the catheter-technique psoas compartment block and the epidural block for analgesia in partial hip replacement surgery. Acta Anaesthesiologica Scandinavica. Jan. 2003;47(1):30-6. Not test of device. [pmid: 12492794].
523 Turpie AG. Pentasaccharide Org31540/SR90107A clinical trials update: lessons for practice. American Heart Journal. Aug. 2001;142(2 Suppl):S9-15. Not hip fracture. [pmid: 11479485].
524 Turpie AGG. Venous thromboembolism prophylaxis: role of factor xa inhibition by fondaparinux. Surgical Technology International. 2004;13:261-7. Not test of device. [pmid: 15744699].
525 Turpie AGG, Bauer KA, Eriksson BI, et al. Fondaparinux vs enoxaparin for the prevention of venous thromboembolism in major orthopedic surgery: a meta-analysis of 4 randomized double-blind studies.[see comment]. Archives of Internal Medicine. Sep. 9. 2002;162(16):1833-40. Not test of device. [pmid: 12196081].
526 Turpie AGG, Eriksson BI, Bauer KA, et al. New pentasaccharides for the prophylaxis of venous thromboembolism: clinical studies. Chest. Dec. 2003;124(6 Suppl):371S-8S. Not RCT. [pmid: 14668420].
527 Upadhyay A, Jain P, Mishra P, et al. Delayed internal fixation of fractures of the neck of the femur in young adults. A prospective, randomised study comparing closed and open reduction. Journal of Bone & Joint Surgery - British Volume. Sep. 2004;86(7):1035-40. Not patient population.
528 Uzzan B, Campos J, Cucherat M, et al. Effects on bone mass of long term treatment with thyroid hormones: a meta-analysis. Journal of Clinical Endocrinology & Metabolism. Dec. 1996;81(12):4278-89. Not hip fracture. [pmid: 8954028].
529 van Vugt AB, Oosterwijk WM, Goris RJ. Predictive value of early scintimetry in intracapsular hip fractures. A prospective study with regard to femoral head necrosis, delayed union and non-union. Archives of Orthopaedic & Trauma Surgery. 1993;113(1):33-8. Not RCT. [pmid: 8117508].
530 van Walraven CV, Paterson JM, Kapral M, et al. Appropriateness of primary total hip and knee replacements in regions of Ontario with high and low utilization rates.[see comment]. CMAJ Canadian Medical Association Journal. Sep. 15. 1996;155(6):697-706. Not hip fracture. [pmid: 8823215].
531 Varley GW, Milner S, Turner GM, et al. Ultrasound assessment of the efficacy of wound drains. Journal of the Royal College of Surgeons of Edinburgh. Apr. 1994;39(2):97-9. Not test of device. [pmid: 7520078].
532 Varley GW, Milner SA. Wound drains in proximal femoral fracture surgery: a randomized prospective trial of 177 patients. Journal of the Royal College of Surgeons of Edinburgh. Dec. 1995;40(6):416-8. Not test of device. [pmid: 8583450].
533 Vasenius J, Pohjonen T, Tormala P, et al. Initial stability of femoral neck osteosynthesis with absorbable self-reinforced poly-L-lactide (SR-PLLA) and metallic screws: a comparative study on 21 cadavers. Journal of Biomedical Materials Research. Feb. 1998;39(2):171-5. Not patient population. [pmid: 9457544].
534 Vathana P, Pakpianpairoj C, Prasartritha T. Comparison of ketoprofen and morphine for postoperative analgesia in orthopaedic patients. Journal of the Medical Association of Thailand. Apr. 1998;81(4):283-7. Not hip fracture. [pmid: 9623023].
535 Venn R, Steele A, Richardson P, et al. Randomized controlled trial to investigate influence of the fluid challenge on duration of hospital stay and perioperative morbidity in patients with hip fractures. British Journal of Anaesthesia. Jan. 2002;88(1):65-71. Not test of device. [pmid: 11881887].
536 Verheyen CCPM, Smulders TC, van Walsum ADP. High secondary displacement rate in the conservative treatment of impacted femoral neck fractures in 105 patients. Archives of Orthopaedic & Trauma Surgery. Apr. 2005;125(3):166-8. Not RCT. [pmid: 15645267].
537 Von Meibom N, Gilson N, Dhapre A, et al. Operative delay for fracture of the hip: a two-centre prospective study. Journal of Bone & Joint Surgery - British Volume. Jan. 2007;89(1):77-9. Not RCT.
538 Vossinakis IC, Badras LS. The external fixator compared with the sliding hip screw for pertrochanteric fractures of the femur.[see comment]. Journal of Bone & Joint Surgery - British Volume. Jan. 2002;84(1):23-9. Not included device.
539 Walheim G, Barrios C, Stark A, et al. Postoperative improvement of walking capacity in patients with trochanteric hip fracture: a prospective analysis 3 and 6 months after surgery. Journal of Orthopaedic Trauma. 1990;4(2):137-43. Not included device. [pmid: 2358927].
540 Wang C-J, Liu H-C, Fu T-H. The effects of extracorporeal shockwave on acute high-energy long bone fractures of the lower extremity. Archives of Orthopaedic & Trauma Surgery. Feb. 2007;127(2):137-42. Not patient population. [pmid: 17053946].
541 Waters TS, Gibbs DMR, Dorrell JH, et al. Percutaneous dynamic hip screw.[see comment]. Injury. Aug. 2006;37(8):751-4. Not RCT. [pmid: 16765961].
542 Weber D, Peter RE. Distal femoral fractures after knee arthroplasty. International Orthopaedics. 1999;23(4):236-9. Not hip fracture. [pmid: 10591943].
543 Weingarten S, Riedinger MS, Sandhu M, et al. Can practice guidelines safely reduce hospital length of stay? Results from a multicenter interventional study. American Journal of Medicine. Jul. 1998;105(1):33-40. Not patient population. [pmid: 9688019].
544 Weinrauch PCL, Moore WR, Shooter DR, et al. Early prosthetic complications after unipolar hemiarthroplasty. ANZ Journal of Surgery. Jun. 2006;76(6):432-5. Not RCT. [pmid: 16768762].
545 Wheeler DL, Croy TJ, Woll TS, et al. Comparison of reconstruction nails for high subtrochanteric femur fracture fixation. Clinical Orthopaedics & Related Research. May. 1997;(338):231-9. Not patient population. [pmid: 9170385].
546 Wihlborg O. Fixation of femoral neck fractures. A four-flanged nail versus threaded pins in 200 cases. Acta Orthopaedica Scandinavica. Oct. 1990;61(5):415-8. Not included device. [pmid: 2239164].
547 Williams HR, Macdonald DA. Audit of thromboembolic prophylaxis in hip and knee surgery. Annals of the Royal College of Surgeons of England. Jan. 1997;79(1):55-7. Not test of device. [pmid: 9038497].
548 Wilson MG, Pei LF, Malone KM, et al. Fixed low-dose versus adjusted higher-dose warfarin following orthopedic surgery. A randomized prospective trial. Journal of Arthroplasty. Apr. 1994;9(2):127-30. Not test of device. [pmid: 8014642].
549 Wong J, Boyd R, Keenan NW, et al. Gait patterns after fracture of the femoral shaft in children, managed by external fixation or early hip spica cast. Journal of Pediatric Orthopedics. Sep-Oct. 2004;24(5):463-71. Not hip fracture. [pmid: 15308893].
550 Wright JG. The treatment of femoral shaft fractures in children: a systematic overview and critical appraisal of the literature. Canadian Journal of Surgery. Jun. 2000;43(3):180-9. Not hip fracture.
551 Wright JG, Wang EEL, Owen JL, et al. Treatments for paediatric femoral fractures: a randomised trial.[see comment]. Lancet. Mar 26-Apr 1. 2005;365(9465):1153-8. Not patient population. [pmid: 15794970].
552 Wu CC, Chen WJ. Treatment of femoral shaft aseptic nonunions: comparison between closed and open bone-grafting techniques. Journal of Trauma-Injury Infection & Critical Care. Jul. 1997;43(1):112-6. Not hip fracture.
553 Wu CC, Shih CH, Chen WJ, et al. Effect of reaming bone grafting on treating femoral shaft aseptic nonunion after plating. Archives of Orthopaedic & Trauma Surgery. 1999;119(5–6):303-7. Not hip fracture. [pmid: 10447628].
554 Yamaguchi K, Masuhara K, Yamasaki S, et al. Cyclic therapy with etidronate has a therapeutic effect against local osteoporosis after cementless total hip arthroplasty. Bone. Jul. 2003;33(1):144-9. Not hip fracture. [pmid: 12919709].
555 Yang X-j, Fei J, Wang Z-g, et al. Experimental study and clinical observation of minimum-contact plate in long bone fracture. Chinese Journal of Traumatology. Apr. 2005;8(2):105-10. Not hip fracture. [pmid: 15769310].
556 Yeo AL, Levy D, Martin FC, et al. Frailty and the biochemical effects of recombinant human growth hormone in women after surgery for hip fracture. Growth Hormone & Igf Research. Dec. 2003;13(6):361-70. Not test of device. [pmid: 14624771].
557 Yiannakopoulos CK, Kanellopoulos AD, Apostolou C, et al. Distal intramedullary nail interlocking: the flag and grid technique. Journal of Orthopaedic Trauma. Jul. 2005;19(6):407-11. Not hip fracture.
558 Yoo M-C, Cho Y-J, Kim K-I, et al. Treatment of unstable peritrochanteric femoral fractures using a 95 degrees angled blade plate.[see comment]. Journal of Orthopaedic Trauma. Nov-Dec. 2005;19(10):687-92. Not RCT. [pmid: 16314715].
559 Yue JJ, Sontich JK, Miron SD, et al. Blood flow changes to the femoral head after acetabular fracture or dislocation in the acute injury and perioperative periods.[see comment]. Journal of Orthopaedic Trauma. Mar-Apr. 2001;15(3):170-6. Not hip fracture. [pmid: 11265006].
560 Yutani Y, Ohashi H, Nishimura N, et al. Clinical effect of etidronate disodium (EHDP) on heterotopic ossification following total hip arthroplasty. Osaka City Medical Journal. Dec. 1995;41(2):63-73. Not test of device. [pmid: 8778647].
561 Zauber NP, Zauber AG, Gordon FJ, et al. Iron supplementation after femoral head replacement for patients with normal iron stores.[see comment]. JAMA. Jan. 22–29. 1992;267(4):525-7. Not a test of device or US device. [pmid: 1729575].
562 Zheng G, Zhang X, Haschtmann D, et al. A robust and accurate two-stage approach for automatic recovery of distal locking holes in computer-assisted intramedullary nailing of femoral shaft fractures. IEEE Transactions on Medical Imaging. Feb. 2008;27(2):171-87. Not test of device. [pmid: 18334439].

## Excluded Observational Studies

1 Aharonoff GB, Koval KJ, Skovron ML, et al. Hip fractures in the elderly: predictors of one year mortality. Journal of Orthopaedic Trauma. Apr. 1997;11(3):162-5. NS at univariate level. [pmid: 9181497].
2 Alarcon T, Gonzalez-Montalvo JI, Barcena A, et al. Further experience of nonagenarians with hip fractures. Injury. Sep. 2001;32(7):555-8. [pmid: 11524088].
3 Alegre-Lopez J, Cordero-Guevara J, Alonso- Valdivielso JL, et al. Factors associated with mortality and functional disability after hip fracture: an inception cohort study. Osteoporosis International. Jul. 2005;16(7):729-36. NS at univariate level. [pmid: 15526089].
4 Arinzon Z, Fidelman Z, Zuta A, et al. Functional recovery after hip fracture in old-old elderly patients. Archives of Gerontology & Geriatrics. May-Jun. 2005;40(3):327-36. not multivariate. [pmid: 15814166].
5 Bass E, French DD, Bradham DD, et al. Risk- adjusted mortality rates of elderly veterans with hip fractures. Annals of Epidemiology. Jul. 2007;17(7):514-9. fracture type not included; femur head included in patient sample. [pmid: 17420142].
6 Baudoin C, Fardellone P, Bean K, et al. Clinical outcomes and mortality after hip fracture: a 2-year follow-up study. Bone. Mar. 1996;18(3 Suppl):149S-57S. fracture type not included. [pmid: 8777081].
7 Beaupre LA, Cinats JG, Jones CA, et al. Does functional recovery in elderly hip fracture patients differ between patients admitted from long-term care and the community?. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. Oct. 2007;62(10):1127-33. fracture type not included.
8 Beloosesky Y, Grinblat J, Epelboym B, et al. Functional gain of hip fracture patients in different cognitive and functional groups. Clinical Rehabilitation. May. 2002;16(3):321-8. too low patient sample. [pmid: 12017519].
9 Berglund-Roden M, Swierstra BA, Wingstrand H, et al. Prospective comparison of hip fracture treatment. 856 cases followed for 4 months in The Netherlands and Sweden. Acta Orthopaedica Scandinavica. Jun. 1994;65(3):287-94. not all fracture types included in regression. [pmid: 8042480].
10 Beringer TRO, Clarke J, Elliott JRM, et al. Outcome following proximal femoral fracture in Northern Ireland. Ulster Medical Journal. Sep. 2006;75(3):200-6. fracture type not included, not multivariate,. [pmid: 16964812].
11 Boereboom FT, Raymakers JA, de Groot RR, et al. Epidemiology of hip fractures in The Netherlands: women compared with men. Osteoporosis International. Nov. 1992;2(6):279-84. retrospective. [pmid: 1421795].
12 Boonen S, Autier P, Barette M, et al. Functional outcome and quality of life following hip fracture in elderly women: a prospective controlled study. Osteoporosis International. Feb. 2004;15(2):87-94. fracture type not included. [pmid: 14605799].
13 Borgquist L, Ceder L, Thorngren KG. Function and social status 10 years after hip fracture. Prospective follow-up of 103 patients. Acta Orthopaedica Scandinavica. Oct. 1990;61(5):404-10. [pmid: 2239162].
14 Borgquist L, Nilsson LT, Lindelow G, et al. Perceived health in hip-fracture patients: a prospective follow-up of 100 patients. Age & Ageing. Mar. 1992;21(2):109-16. too low patient sample. [pmid: 1575088].
15 Borkan JM, Quirk M. Expectations and outcomes after hip fracture among the elderly. International Journal of Aging & Human Development. 1992;34(4):339-50. [pmid: 1607220].
16 Broos PL, Van Haaften KI, Stappaerts KH, et al. Hip fractures in the elderly. Mortality, functional results and social readaptation. International Surgery. Jul-Sep. 1989;74(3):191-4. fracture type not included. [pmid: 2606625].
17 Carriere G. Hip fracture outcomes in the household population. Health Reports. Nov. 2007;18(4):37-42. fracture type not included. [pmid: 18074996].
18 Chariyalertsak S, Suriyawongpisal P, Thakkinstain A. Mortality after hip fractures in Thailand. International Orthopaedics. 2001;25(5):294-7. NS at univariate level. [pmid: 11794262].
19 Chin RPH, Ng BHP, Cheung LPC. Factors predicting rehabilitation outcomes of elderly patients with hip fracture. Hong Kong Medical Journal. Jun. 2008;14(3):209-15. fracture type not included. [pmid: 18525090].
20 Clayer MT, Bauze RJ. Morbidity and mortality following fractures of the femoral neck and trochanteric region: analysis of risk factors.[see comment]. Journal of Trauma-Injury Infection & Critical Care. Dec. 1989;29(12):1673-8. retrospective.
21 Cree M, Carriere KC, Soskolne CL, et al. Functional dependence after hip fracture. American Journal of Physical Medicine & Rehabilitation. Oct. 2001;80(10):736-43. fracture type not included. [pmid: 11562555].
22 Cree M, Soskolne CL, Belseck E, et al. Mortality and institutionalization following hip fracture. Journal of the American Geriatrics Society. Mar. 2000;48(3):283-8. fracture type not included. [pmid: 10733054].
23 Crotty M, Miller M, Whitehead C, et al. Hip fracture treatments--what happens to patients from residential care?. Journal of Quality in Clinical Practice. Dec. 2000;20(4):167-70. not multivariate. [pmid: 11207957].
24 Cserhati P, Fekete K, Berglund-Roden M, et al. Hip fractures in Hungary and Sweden - differences in treatment and rehabilitation. International Orthopaedics. 2002;26(4):222-8. not mutivariate, multivariate only for fem neck. [pmid: 12185524].
25 Cumming RG, Klineberg R, Katelaris A. Cohort study of risk of institutionalisation after hip fracture. Australian & New Zealand Journal of Public Health. Dec. 1996;20(6):579-82. [pmid: 9117962].
26 Cummings SR, Phillips SL, Wheat ME, et al. Recovery of function after hip fracture. The role of social supports. Journal of the American Geriatrics Society. Sep. 1988;36(9):801-6. [pmid: 3411063].
27 Curry LC, Hogstel MO, Davis GC. Functional status in older women following hip fracture. Journal of Advanced Nursing. May. 2003;42(4):347-54. [pmid: 12752879].
28 Dasch B, Endres HG, Maier C, et al. Fracture-related hip pain in elderly patients with proximal femoral fracture after discharge from stationary treatment. European Journal of Pain: Ejp. Feb. 2008;12(2):149-56. fracture type not included in analysis. [pmid: 17475523].
29 Di Monaco M, Vallero F, Di Monaco R, et al. Body mass index and functional recovery after hip fracture: a survey study of 510 women. Aging-Clinical & Experimental Research. Feb. 2006;18(1):57-62. retrospective. [pmid: 16608137].
30 Diamond TH, Thornley SW, Sekel R, et al. Hip fracture in elderly men: prognostic factors and outcomes.[see comment]. Medical Journal of Australia. Oct. 20. 1997;167(8):412-5. [pmid: 9364155].
31 Endo Y, Aharonoff GB, Zuckerman JD, et al. Gender differences in patients with hip fracture: a greater risk of morbidity and mortality in men.[see comment]. Journal of Orthopaedic Trauma. Jan. 2005;19(1):29-35. NS at univariate level. [pmid: 15668581].
32 Fierens J, Broos PLO. Quality of life after hip fracture surgery in the elderly. Acta Chirurgica Belgica. Jul-Aug. 2006;106(4):393-6. retrospective, not multivariate. [pmid: 17017690].
33 Finsen V, Borset M, Rossvoll I. Mobility, survival and nursing-home requirements after hip fracture. Annales Chirurgiae et Gynaecologiae. 1995;84(3):291-4. [pmid: 8702204].
34 Folden S, Tappen R. Factors influencing function and recovery following hip repair surgery.[see comment]. Orthopaedic Nursing. Jul-Aug. 2007;26(4):234-41. [pmid: 17882100].
35 Formiga F, Lopez-Soto A, Sacanella E, et al. Mortality and morbidity in nonagenarian patients following hip fracture surgery. Gerontology. Jan-Feb. 2003;49(1):41-5. not all fracture types, too small patient population. [pmid: 12457049].
36 Fox KM, Hawkes WG, Hebel JR, et al. Mobility after hip fracture predicts health outcomes. Journal of the American Geriatrics Society. Feb. 1998;46(2):169-73. fracture type not included. [pmid: 9475444].
37 Fredman L, Hawkes WG, Black S, et al. Elderly patients with hip fracture with positive affect have better functional recovery over 2 years. Journal of the American Geriatrics Society. Jul. 2006;54(7):1074-81. fracture type not included. [pmid: 16866678].
38 Furstenberg AL, Mezey MD. Differences in outcome between black and white elderly hip fracture patients. Journal of Chronic Diseases. 1987;40(10):931-8. retrospective. [pmid: 3038943].
39 Givens JL, Sanft TB, Marcantonio ER. Functional recovery after hip fracture: the combined effects of depressive symptoms, cognitive impairment, and delirium. Journal of the American Geriatrics Society. Jun. 2008;56(6):1075-9. fracture type not included. [pmid: 18422945].
40 Goldstein FC, Strasser DC, Woodard JL, et al. Functional outcome of cognitively impaired hip fracture patients on a geriatric rehabilitation unit.[see comment]. Journal of the American Geriatrics Society. Jan. 1997;45(1):35-42. [pmid: 8994485].
41 Greatorex IF, Gibbs AC. Proximal femoral fractures: some determinants of outcome. Journal of Epidemiology & Community Health. Dec. 1988;42(4):365-9. not all fracture types included. [pmid: 3256579].
42 Guccione AA, Fagerson TL, Anderson JJ. Regaining functional independence in the acute care setting following hip fracture. Physical Therapy. Aug. 1996;76(8):818-26. fracture type not included. [pmid: 8710961].
43 Haentjens P, Autier P, Barette M, et al. Survival and functional outcome according to hip fracture type: a one-year prospective cohort study in elderly women with an intertrochanteric or femoral neck fracture. Bone. Dec. 2007;41(6):958-64. not multivariate. [pmid: 17913614].
44 Hakkinen A, Heinonen M, Kautiainen H, et al. Effect of cognitive impairment on basic activities of daily living in hip fracture patients: a 1-year follow-up. Aging-Clinical & Experimental Research. Apr. 2007;19(2):139-44. fracture type not included. [pmid: 17446725].
45 Hasegawa Y, Suzuki S, Wingstrand H. Risk of mortality following hip fracture in Japan. Journal of Orthopaedic Science. Mar. 2007;12(2):113-7. fracture type not included. [pmid: 17393264].
46 Heikkinen T, Parker M, Jalovaara P. Hip fractures in Finland and Great Britain--a comparison of patient characteristics and outcomes. International Orthopaedics. 2001;25(6):349-54. not multivariate. [pmid: 11820439].
47 Heikkinen T, Partanen J, Ristiniemi J, et al. Evaluation of 238 consecutive patients with the extended data set of the Standardised Audit for Hip Fractures in Europe (SAHFE). Disability & Rehabilitation. Sep 30-Oct 15. 2005;27(18–19):1107-15. not multivariate. [pmid: 16278179].
48 Holmes J, House A. Psychiatric illness predicts poor outcome after surgery for hip fracture: a prospective cohort study. Psychological Medicine. Jul. 2000;30(4):921-9. fracture type not included. [pmid: 11037100].
49 Holt G, Macdonald D, Fraser M, et al. Outcome after surgery for fracture of the hip in patients aged over 95 years. Journal of Bone & Joint Surgery - British Volume. Aug. 2006;88(8):1060-4. fracture type included/not reported.
50 Holt G, Smith R, Duncan K, et al. Gender differences in epidemiology and outcome after hip fracture: evidence from the Scottish Hip Fracture Audit. Journal of Bone & Joint Surgery - British Volume. Apr. 2008;90(4):480-3. fracture type included, but not reported.
51 Holt G, Smith R, Duncan K, et al. Epidemiology and outcome after hip fracture in the under 65s-evidence from the Scottish Hip Fracture Audit. Injury. Oct. 2008;39(10):1175-81. fracture type included, but not reported. [pmid: 18703186].
52 Hubble M, Little C, Prothero D, et al. Predicting the prognosis after proximal femoral fracture. Annals of the Royal College of Surgeons of England. Sep. 1995;77(5):355-7. fracture type not included. [pmid: 7486762].
53 Huuskonen J, Kroger H, Arnala I, et al. Characteristics of male hip fracture patients. Annales Chirurgiae et Gynaecologiae. 1999;88(1):48-53. not multivariate. [pmid: 10230683].
54 Ingemarsson AH, Frandin K, Mellstrom D, et al. Walking ability and activity level after hip fracture in the elderly--a follow-up. Journal of Rehabilitation Medicine. Mar. 2003;35(2):76-83. too small patient sample. [pmid: 12691337].
55 Ishida Y, Kawai S, Taguchi T. Factors affecting ambulatory status and survival of patients 90 years and older with hip fractures. Clinical Orthopaedics & Related Research. Jul. 2005;(436):208-15. [pmid: 15995443].
56 Jalovaara P, Berglund-Roden M, Wingstrand H, et al. Treatment of hip fracture in Finland and Sweden. Prospective comparison of 788 cases in three hospitals. Acta Orthopaedica Scandinavica. Oct. 1992;63(5):531-5. not multivariate. [pmid: 1441950].
57 Kagaya H, Takahashi H, Sugawara K, et al. Predicting outcomes after hip fracture repair. American Journal of Physical Medicine & Rehabilitation. Jan. 2005;84(1):46-51. [pmid: 15632488].
58 Katelaris AG, Cumming RG. Health status before and mortality after hip fracture. American Journal of Public Health. Apr. 1996;86(4):557-60. fracture type not included. [pmid: 8604790].
59 Kauffman TL, Albright L, Wagner C. Rehabilitation outcomes after hip fracture in persons 90 years old and older. Archives of Physical Medicine & Rehabilitation. Jun. 1987;68(6):369-71. retrospective, too small patient sample. [pmid: 3592951].
60 Keene GS, Parker MJ, Pryor GA. Mortality and morbidity after hip fractures.[see comment]. BMJ. Nov. 13. 1993;307(6914):1248-50. not multivariate. [pmid: 8166806].
61 Kernek CB, Baele JR, Throop FB, et al. Comparison of hip fracture mortality: 1946 to 1955 vs. 1982 to 1986. Indiana Medicine. May. 1990;83(5):332-5. retrospective. [pmid: 2341704].
62 Kirke PN, Sutton M, Burke H, et al. Outcome of hip fracture in older Irish women: a 2-year follow-up of subjects in a case-control study. Injury. Jun. 2002;33(5):387-91. fracture type not included. [pmid: 12095716].
63 Kitamura S, Hasegawa Y, Suzuki S, et al. Functional outcome after hip fracture in Japan. Clinical Orthopaedics & Related Research. Mar. 1998;(348):29-36. fracture type not included. [pmid: 9553530].
64 Koike Y, Imaizumi H, Takahashi E, et al. Determining factors of mortality in the elderly with hip fractures. Tohoku Journal of Experimental Medicine. Jun. 1999;188(2):139-42. retrospective, too small patient sample. [pmid: 10526875].
65 Koot VC, Peeters PH, de Jong JR, et al. Functional results after treatment of hip fracture: a multicentre, prospective study in 215 patients. European Journal of Surgery. Jun. 2000;166(6):480-5. fracture type not included. [pmid: 10890545].
66 Kuokkanen HO, Korkala OL. Factors affecting survival of patients with hip fractures. Acta Orthopaedica Belgica. 1992;58(4):425-8. [pmid: 1485507].
67 Latham NK, Jette DU, Warren RL, et al. Pattern of functional change during rehabilitation of patients with hip fracture. Archives of Physical Medicine & Rehabilitation. Jan. 2006;87(1):111-6. retrospective. [pmid: 16401448].
68 Lawrence VA, Hilsenbeck SG, Noveck H, et al. Medical complications and outcomes after hip fracture repair. Archives of Internal Medicine. Oct. 14. 2002;162(18):2053-7. retrospective. [pmid: 12374513].
69 Lieberman D, Lieberman D. Rehabilitation following hip fracture surgery: a comparative study of females and males. Disability & Rehabilitation. Jan. 21. 2004;26(2):85-90. not multivariate. [pmid: 14668144].
70 Lieberman JR, Romano PS, Mahendra G, et al. The treatment of hip fractures: variations in care. Clinical Orthopaedics & Related Research. Jan. 2006;442:239-44. retrospective. [pmid: 16394767].
71 Lyritis GP, Johnell O. Orthopaedic management of hip fracture. Bone. 1993;14(Suppl 1):S11-7. not multivariate. [pmid: 8110514].
72 Magaziner J, Fredman L, Hawkes W, et al. Changes in functional status attributable to hip fracture: a comparison of hip fracture patients to community-dwelling aged. American Journal of Epidemiology. Jun. 1. 2003;157(11):1023-31. fracture type not included. [pmid: 12777366].
73 Magaziner J, Hawkes W, Hebel JR, et al. Recovery from hip fracture in eight areas of function.[see comment]. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. Sep. 2000;55(9):M498-507. fracture type not included.
74 Magaziner J, Lydick E, Hawkes W, et al. Excess mortality attributable to hip fracture in white women aged 70 years and older. American Journal of Public Health. Oct. 1997;87(10):1630-6. fracture type not included. [pmid: 9357344].
75 Magaziner J, Simonsick EM, Kashner TM, et al. Predictors of functional recovery one year following hospital discharge for hip fracture: a prospective study. Journal of Gerontology. May. 1990;45(3):M101-7. fracture type not included. [pmid: 2335719].
76 Marottoli RA, Berkman LF, Cooney LM Jr. Decline in physical function following hip fracture. Journal of the American Geriatrics Society. Sep. 1992;40(9):861-6. too small patient sample. [pmid: 1512379].
77 Marottoli RA, Berkman LF, Leo-Summers L, et al. Predictors of mortality and institutionalization after hip fracture: the New Haven EPESE cohort. Established Populations for Epidemiologic Studies of the Elderly. American Journal of Public Health. Nov. 1994;84(11):1807-12. too small patient sample. [pmid: 7977922].
78 Matsueda M, Ishii Y. The relationship between dementia score and ambulatory level after hip fracture in the elderly. American Journal of Orthopedics. Sep. 2000;29(9):691-3. retrospective. [pmid: 11008865].
79 Meyer HE, Tverdal A, Falch JA. Body height, body mass index, and fatal hip fractures: 16 years' follow-up of 674,000 Norwegian women and men. Epidemiology. May. 1995;6(3):299-305. fracture type not included. [pmid: 7619940].
80 Meyer HE, Tverdal A, Falch JA, et al. Factors associated with mortality after hip fracture.[see comment]. Osteoporosis International. 2000;11(3):228-32. fracture type not included. [pmid: 10824238].
81 Michel JP, Hoffmeyer P, Klopfenstein C, et al. Prognosis of functional recovery 1 year after hip fracture: typical patient profiles through cluster analysis.[see comment]. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. Sep. 2000;55(9):M508-15. fracture type not included.
82 Mizrahi EH, Fleissig Y, Arad M, et al. Functional outcome of elderly hip fracture patients: does diabetes matter?. Archives of Gerontology & Geriatrics. Sep-Oct. 2006;43(2):165-73. not stated if fracture type was entered. [pmid: 16359740].
83 Moncada LV, Andersen RE, Franckowiak SC, et al. The impact of cognitive impairment on short-term outcomes of hip fracture patients. Archives of Gerontology & Geriatrics. Jul-Aug. 2006;43(1):45-52. too small patient sample. [pmid: 16256217].
84 Mortimore E, Haselow D, Dolan M, et al. Amount of social contact and hip fracture mortality. Journal of the American Geriatrics Society. Jun. 2008;56(6):1069-74. fracture type not included. [pmid: 18410322].
85 Mossey JM, Mutran E, Knott K, et al. Determinants of recovery 12 months after hip fracture: the importance of psychosocial factors. American Journal of Public Health. Mar. 1989;79(3):279-86. NS at univariate level. [pmid: 2916712].
86 Mullen JO, Mullen NL. Hip fracture mortality. A prospective, multifactorial study to predict and minimize death risk. Clinical Orthopaedics & Related Research. Jul. 1992;(280):214-22. not multivariate. [pmid: 1611747].
87 Munin MC, Begley A, Skidmore ER, et al. Influence of rehabilitation site on hip fracture recovery in community-dwelling subjects at 6-month follow-up. Archives of Physical Medicine & Rehabilitation. Jul. 2006;87(7):1004-6. [pmid: 16813791].
88 Nettleman MD, Alsip J, Schrader M, et al. Predictors of mortality after acute hip fracture. Journal of General Internal Medicine. Dec. 1996;11(12):765-7. retrospective. [pmid: 9016427].
89 Nevalainen TH, Hiltunen LA, Jalovaara P. Functional ability after hip fracture among patients home-dwelling at the time of fracture. Central European Journal of Public Health. Dec. 2004;12(4):211-6. not multivariate. [pmid: 15666460].
90 Nguyen-Oghalai TU, Ottenbacher KJ, Granger CV, et al. Impact of osteoarthritis on rehabilitation for persons with hip fracture. Arthritis & Rheumatism. Dec. 15. 2006;55(6):920-4. retrospective. [pmid: 17139638].
91 Olmeda A, Greco F, Timar J, et al. Death rate in patients submitted to the surgical treatment of fracture of the proximal femur. Chirurgia Degli Organi di Movimento. Apr-Jun. 1995;80(2):179-81. not multivariate. [pmid: 7587519].
92 Paksima N, Koval KJ, Aharanoff G, et al. Predictors of mortality after hip fracture: a 10-year prospective study. Bulletin of the NYU Hospital for Joint Diseases. 2008;66(2):111-7. fracture type not reported if included. [pmid: 18537780].
93 Pande I, Scott DL, O'Neill TW, et al. Quality of life, morbidity, and mortality after low trauma hip fracture in men. Annals of the Rheumatic Diseases. Jan. 2006;65(1):87-92. [pmid: 16079173].
94 Parker MJ, Palmer CR. Prediction of rehabilitation after hip fracture.[see comment]. Age & Ageing. Mar. 1995;24(2):96-8. fracture type not included. [pmid: 7793343].
95 Penrod JD, Litke A, Hawkes WG, et al. The association of race, gender, and comorbidity with mortality and function after hip fracture. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. Aug. 2008;63(8):867-72. fracture type included/not reported.
96 Pioli G, Barone A, Giusti A, et al. Predictors of mortality after hip fracture: results from 1-year follow-up. Aging-Clinical & Experimental Research. Oct. 2006;18(5):381-7. NS at univariate level. [pmid: 17167302].
97 Poor G, Atkinson EJ, Lewallen DG, et al. Age-related hip fractures in men: clinical spectrum and short-term outcomes. Osteoporosis International. 1995;5(6):419-26. too small patient sample. [pmid: 8695962].
98 Poor G, Atkinson EJ, O'Fallon WM, et al. Determinants of reduced survival following hip fractures in men. Clinical Orthopaedics & Related Research. Oct. 1995;(319):260-5. retrospective. [pmid: 7554638].
99 Richmond J, Aharonoff GB, Zuckerman JD, et al. Mortality risk after hip fracture. Journal of Orthopaedic Trauma. Jan. 2003;17(1):53-6. not multivariate. [pmid: 12499968].
100 Robbins JA, Biggs ML, Cauley J. Adjusted mortality after hip fracture: From the cardiovascular health study. Journal of the American Geriatrics Society. Dec. 2006;54(12):1885-91. fracture type not included, non-hip fracture comparison. [pmid: 17198494].
101 Roche JJW, Wenn RT, Sahota O, et al. Effect of comorbidities and postoperative complications on mortality after hip fracture in elderly people: prospective observational cohort study. BMJ. Dec. 10. 2005;331(7529):1374. fracture type not included in regression, focus on complications. [pmid: 16299013].
102 Rolland Y, Pillard F, Lauwers-Cances V, et al. Rehabilitation outcome of elderly patients with hip fracture and cognitive impairment. Disability & Rehabilitation. Apr. 8. 2004;26(7):425-31. [pmid: 15204479].
103 Rosell PAE, Parker MJ. Functional outcome after hip fracture. A 1-year prospective outcome study of 275 patients. Injury. Jul. 2003;34(7):529-32. not multivariate. [pmid: 12832181].
104 Saarenpaa I, Heikkinen T, Partanen J, et al. Hip fracture treatment in Oulu--one-year survey with four-month follow-up. Scandinavian Journal of Surgery: SJS. 2006;95(1):61-7. not multivariate, validation study. [pmid: 16579258].
105 Sakamoto K, Nakamura T, Hagino H, et al. Report on the Japanese Orthopaedic Association's 3-year project observing hip fractures at fixed-point hospitals. Journal of Orthopaedic Science. Mar. 2006;11(2):127-34. not multivariate. [pmid: 16568383].
106 Schurch MA, Rizzoli R, Mermillod B, et al. A prospective study on socioeconomic aspects of fracture of the proximal femur. Journal of Bone & Mineral Research. Dec. 1996;11(12):1935-42. not multivariate, fracture type not in multivariate models. [pmid: 8970896].
107 Schuurmans MJ, Duursma SA, Shortridge-Baggett LM, et al. Elderly patients with a hip fracture: the risk for delirium. Applied Nursing Research. May. 2003;16(2):75-84. not multivariate. [pmid: 12764718].
108 Sernbo I, Johnell O. Consequences of a hip fracture: a prospective study over 1 year. Osteoporosis International. May. 1993;3(3):148-53. fracture type not included in analysis. [pmid: 8481591].
109 Shah MR, Aharonoff GB, Wolinsky P, et al. Outcome after hip fracture in individuals ninety years of age and older. Journal of Orthopaedic Trauma. Jan. 2001;15(1):34-9. multivariate results not clear/reported, patient sample for one arm 76. [pmid: 11147685].
110 Shyu Y-IL, Chen M-C, Liang J, et al. Predictors of functional recovery for hip fractured elders during 12 months following hospital discharge: a prospective study on a Taiwanese sample. Osteoporosis International. Jun. 2004;15(6):475-82. fracture type not included, too small patient sample. [pmid: 15205719].
111 Soderqvist A, Miedel R, Ponzer S, et al. The influence of cognitive function on outcome after a hip fracture. Journal of Bone & Joint Surgery - American Volume. Oct. 2006;88(10):2115-23. not all fracture types.
112 Suriyawongpaisal P, Chariyalertsak S, Wanvarie S. Quality of life and functional status of patients with hip fractures in Thailand. Southeast Asian Journal of Tropical Medicine & Public Health. Jun. 2003;34(2):427-32. not multivariate. [pmid: 12971576].
113 Svensson O, Stromberg L, Ohlen G, et al. Prediction of the outcome after hip fracture in elderly patients. Journal of Bone & Joint Surgery - British Volume. Jan. 1996;78(1):115-8. fracture type not included.
114 Tanaka J, Tokimura F, Seki N. Outcomes of hip fracture surgery in patients aged > or = 90 years. Orthopedics. Jan. 2003;26(1):55-8. [pmid: 12555835].
115 Thorngren KG, Ceder L, Svensson K. Predicting results of rehabilitation after hip fracture. A ten-year follow-up study. Clinical Orthopaedics & Related Research. Feb. 1993;(287):76-81. [pmid: 8448963].
116 Todd CJ, Freeman CJ, Camilleri-Ferrante C, et al. Differences in mortality after fracture of hip: the east Anglian audit.[see comment]. BMJ. Apr. 8. 1995;310(6984):904-8. not all fracture types. [pmid: 7719180].
117 Tolo ET, Bostrom MP, Simic PM, et al. The short term outcome of elderly patients with hip fractures. International Orthopaedics. 1999;23(5):279-82. too small patient sample. [pmid: 10653294].
118 Trombetti A, Herrmann F, Hoffmeyer P, et al. Survival and potential years of life lost after hip fracture in men and age-matched women. Osteoporosis International. Sep. 2002;13(9):731-7. NS at univariate level. [pmid: 12195537].
119 Tsuboi M, Hasegawa Y, Suzuki S, et al. Mortality and mobility after hip fracture in Japan: a ten-year follow-up. Journal of Bone & Joint Surgery - British Volume. Apr. 2007;89(4):461-6. fracture type not included in analysis.
120 Umarji SIM, Lankester BJA, Prothero D, et al. Recovery after hip fracture. Injury. Aug. 2006;37(8):712-7. not multivariate, fracture type not included. [pmid: 16765960].
121 van Balen R, Steyerberg EW, Polder JJ, et al. Hip fracture in elderly patients: outcomes for function, quality of life, and type of residence. Clinical Orthopaedics & Related Research. Sep. 2001;(390):232-43. [pmid: 11550871].
122 van de Kerkhove MP, Antheunis PS, Luitse JSK, et al. Hip fractures in nonagenarians: perioperative mortality and survival. Injury. Feb. 2008;39(2):244-8. retrospective. [pmid: 17953970].
123 Vestergaard P, Rejnmark L, Mosekilde L. Increased mortality in patients with a hip fracture-effect of pre-morbid conditions and post-fracture complications. Osteoporosis International. Dec. 2007;18(12):1583-93. fracture type not included. [pmid: 17566814].
124 Vestergaard P, Rejnmark L, Mosekilde L. Has mortality after a hip fracture increased?. Journal of the American Geriatrics Society. Nov. 2007;55(11):1720-6. fracture type not included. [pmid: 17916118].
125 Vidal EIO, Coeli CM, Pinheiro RS, et al. Mortality within 1 year after hip fracture surgical repair in the elderly according to postoperative period: a probabilistic record linkage study in Brazil. Osteoporosis International. Oct. 2006;17(10):1569-76. fracture type not included. [pmid: 16871434].
126 von Friesendorff M, Besjakov J, Akesson K. Long- term survival and fracture risk after hip fracture: a 22-year follow-up in women. Journal of Bone & Mineral Research. Nov. 2008;23(11):1832-41. fracture type not included. [pmid: 18597630].
127 Walker N, Norton R, Vander Hoorn S, et al. Mortality after hip fracture: regional variations in New Zealand. New Zealand Medical Journal. Jul. 23. 1999;112(1092):269-71. fracture type not included. [pmid: 10472890].
128 Weatherall M. Case mix and outcome for patients with fracture of the proximal femur. New Zealand Medical Journal. Oct. 27. 1993;106(966):451-2. not multivariate. [pmid: 8233177].
129 Weatherall M. One year follow up of patients with fracture of the proximal femur. New Zealand Medical Journal. Aug. 10. 1994;107(983):308-9. not multivariate. [pmid: 8052465].
130 Wehren LE, Hawkes WG, Orwig DL, et al. Gender differences in mortality after hip fracture: the role of infection. Journal of Bone & Mineral Research. Dec. 2003;18(12):2231-7. fracture type not included. [pmid: 14672359].
131 White BL, Fisher WD, Laurin CA. Rate of mortality for elderly patients after fracture of the hip in the 1980's. Journal of Bone & Joint Surgery - American Volume. Dec. 1987;69(9):1335-40. not multivariate.
132 Williams MA, Oberst MT, Bjorklund BC. Early outcomes after hip fracture among women discharged home and to nursing homes. Research in Nursing & Health. Jun. 1994;17(3):175-83. fracture type not included, too small patient sample. [pmid: 8184129].
133 Wolinsky FD, Fitzgerald JF, Stump TE. The effect of hip fracture on mortality, hospitalization, and functional status: a prospective study. American Journal of Public Health. Mar. 1997;87(3):398-403. fracture type not included. [pmid: 9096540].
134 Yarden PE, Finkel MG, Raps CS, et al. Adverse outcome of hip fractures in older schizophrenic patients. American Journal of Psychiatry. Mar. 1989;146(3):377-9. [pmid: 2919696].
135 Youm T, Aharonoff G, Zuckerman JD, et al. Effect of previous cerebrovascular accident on outcome after hip fracture. Journal of Orthopaedic Trauma. Jun-Jul. 2000;14(5):329-34. NS at univariate level. [pmid: 10926239].