# Quorum Statement and Evidence Tables

Appendix Figure E1 QUORUM statement data for RCT literature

Appendix Figure E2 QUORUM statement data for observational literature

Appendix Table E1 Observational studies

Author, Year Country | Study Aim | Patient N Followup | Patient Population | Fracture Type | Surgical Treatment | Site | Reported Results
Focused Research Question
Karagiannis, 2006^1^ Greece | Examine relationship between patient factors, fracture type, and long-term mortality | N=499 10 years | 60+ years, excluded subtrochanteric, pathologic, nonindex, and high trauma fractures | FN, IT, no sub-types | None reported | Single hospital site | Age, sex, type of fracture, heart failure were independent predictors of 10 year mortality. IT had 1.37 times higher probability of mortality. Did not adjust for functional or cognitive status.
Cornwall, 2004^2^ United States | Examine the relationship between fracture type, patient characteristics, and mortality and functional outcomes | N=804 6 months | 50+ years, excluding bilateral, pathologic, multiple trauma, non-index, | FN – displaced and not displaced; IT – stable and unstable | Yes, 100% correlated with type of fracture, IT and hemi | Single hospital site | Nondisplaced fractures more likely in younger patients. Preinjury functional dependence predicted mortality. Age, gender, fracture type, comorbidities, perioperative factors were not predictive. Age and preinjury functional dependence predicted functional outcomes.
Fox, 1999^3^ United States | Examine relationship between fracture type, patient characteristics and mortality and functional outcomes | N=923 12 months | 65+ years, community dwelling, ambulatory. | FN, IT, no sub-types | Internal fixation, hemi, THA | 7 hospital sites | IT had lower recovery at 2 months, higher mortality at 2 and 6 months. No differences between fracture types remained at 12 months. Surgical treatment did not affect the model when added.
Generalized Research Question – Fracture type Included in multivariate analysis
Heikkinen, 2004^4^ Finland | Examine predictors of mortality and function after hip fracture | N=2,279 4 months | 50+ years | Displaced/undisplaced FN, IT 2 or multi- fragment, subtroch | Multiple internal fixation, hemi, THA | 6 hospital sites | Prefracture residence, mobility, morbidity, and age were predictive of 4 month mortality and function. Fracture type and surgical method were not predictive. Differences in hospital preferences for surgical treatment found. Potential effects of possible multicollinearity between variables not discussed.
Hannan, 2001^5^ United States | Examine patient factors for risk factors for 6 months mortality and functional status for hip fracture patients, | N=571 6 months | 50+ years, no concurrent major injuries, pathological fractures, fractures, isolated pelvic or acetabular fractures, bilateral fractures, nonindex fractures | Displaced and nondisplaced FN, IT without sub- types | Treatment 100% correlated with fracture type: IF, hemi | 4 hospital sites. Outcomes adjusted by site. | Age, prefracture mobility, and nursing home residence predicted mobility. APACHE score, low prefracture mobility, and paid help at home were predictive of mortality. When the two outcomes were combined as adverse outcomes, dementia was also predictive. Fracture type was not a significant predictor.
Koval, 1998^6^ United States | Examine predictors of ADL/IADLs after hip fracture | N=338 12 months | 65+ years, community dwelling, ambulatory, cognitively intact with nonpathological fractures | FN, IT, no sub-types | None reported | Single hospital site | Age and prefracture ADLs/IADLs predicted recovery at 3 and 6 months. Patient age was the only independent predictor at 1 year. Fracture type was not a predictor.
Koval, 1996^7^ United States | Examine predictors of dependency after hip fracture | N=431 12 months | 65+ years, community dwelling, ambulatory, cognitively intact with nonpathological fractures | FN, IT, no sub-types | None reported | Single hospital site | Age, prefracture independence in ADL/IADLs, number of comorbidities were predictive at 3, 6, and 12 months of patient regaining prefracture independence. Fracture type was not significant
Koval, 1995^8^ United States | Examine predictors of ambulatory ability after hip fracture | N=336 12–18 months | 65+ years, community dwelling, ambulatory, cognitively intact with non- pathological fractures | FN, IT, no sub-types | Treatment 100% correlated with fracture type: IF, hemi | Single hospital site | Fracture type not predictive of a decline in ambulatory status for all patients or previous community ambulators. However, IT was borderline predictive of a patient becoming household or nonfunctional ambulators. Age, prefracture mobility, ASA rating were also predictors.
Borgquist, 1991^9^ Sweden | Examine predictors of independent ADLs after hip fracture in the elderly | N=827 4 months | 50+ years, community dwelling prior to fracture | FN, IT, no sub-types | Yes, treatment reported 100% correlated with fracture type | Single hospital site | Age, gender, and living with someone predicted living at home at 4 months. Type of fracture, prefracture mobility and ADLs were not predictive. Age, FN fracture, gender predicted independent ADLs at 4 months.

FN = femoral neck fracture

IT = intertrochanteric fracture

Appendix Table E2 Femoral neck evidence-1

Author, Year | Comparison | Country | N Enrolled | Inclusion | Exclusion | Average Age Range/SD % Female | Power Calculation Met Target
Node 4 Displaced - Arthroplasty – Hemi Choices
Emery, 1991^10^ | Cement stem vs. not, bipolar hemi | England | 53 | Active, independently mobile with displaced femoral neck fracture | Admitted from NH, use more than one walking stick | 79 61–96 87% | No
Livesley, 1993^11^ | Ceramic coated vs. not, bipolar hemi | United Kingdom | 82 | Displaced femoral neck fracture | None listed | 81 SD 7.8 NR | No
Node 4 Displaced – Internal Fixation - Cemented vs. Not Cemented Screws
Mattsson, 2006^12^ | IF - Calcium phosphate vs. no c.p. | Sweden | 118 | Displaced femoral neck fracture, ambulatory without walking aid (or with one cane) 60+ years of age, surgical procedure within 72 hours of admission, normal contralateral hip | Senility, earlier hip surgery, soft tissue infection at operative site, ongoing radiotherapy or chemotherapy due to malignancy, pathological fracture, clotting disorder, corticosteroid treatment exceeding 5 mg per day, concurrent fracture that would affect postoperative functional outcome, serious concomitant illness or mental instability, neurosensory, neuromuscular or musculoskeletal deficiency that might limit ability to perform objective functional tests | NR 60–98 81% | Yes Yes
Mattson, 2003^13^ | IF - Calcium phosphate vs. no c.p. | Sweden | 40 | Low energy trauma, pre- fracture ambulatory without aid (or with one cane) | Senility, pathological fracture, concurrent fracture, bilateral | 78 62–92 83% | No
Node 3 Displaced - Arthroplasty – Uni vs. Bipolar Hemi
Raia, 2003^14^ | Uni vs. bipolar hemi (cemented stems) | United States | 115 | 65+ years with displaced femoral fracture, ambulatory | Dementia, pathologic fracture, concurrent lower extremity fracture, NH residence | 82 65–101 72% | No
Cornell, 1998^15^ | Uni vs. bipolar hemi (cemented stems) | United States | 48 | 65+ with displaced femoral neck fracture (early results but full study not reported) | Previous ipsilateral hip surgery, pathological fracture, mentally incompetent patients | 78 62–97 75% | No
Node 3 Inclusive – Internal Fixation - Hook Pins vs. Screws
Mjorud, 2006^16^ | IF - 2 hook pin vs. 3 screws | Sweden | 199 | Cervical hip fracture | Non-healed bilateral, pathological fracture, combined with trochanteric component, joint disease, unable to reduce satisfactorily | U 79, D 81 U 28–101 D 53–101 76% | No
Lykke, 2003^17^ | IF - 2 hook pin vs. 3 screws | Norway | 278 | Femoral neck fracture | Bilateral, pathological fracture, concomitant or combined fractures, irreducible fractures | 82 27–101 82% | No
Herngren, 1992^18^ | IF - 2 hook pin vs. 2 screws | Sweden | 179 | Femoral neck fractures | Pathologic fractures, unable to reduce satisfactorily | 78 28–97 63% | No
Olerud, 1991^19^ | IF - 2 hook pin vs. 2 screws | Sweden | 115 | Femoral neck fractures | None listed | 80 SD 9 84% | No
Node 3 Inclusive – Internal Fixation - Screws vs. Screws
Lagerby, 1998^20^ | IF - 2 vs. 3 screws | Sweden | 268 | Femoral neck fractures | Pathological fractures | 81 31–99 67% | Yes Yes
Rehnberg, 1989^21^ | IF - 2 vs. 2 screws | Sweden | 222 | Femoral neck fracture | Pathologic fractures, unable to reduce satisfactorily, fracture older than 1 week | 80 55–98 75% | Yes
Node 2 Displaced - Arthroplasty - Hemi vs. Total Hip
Baker, 2006^22^ | Hemi (cemented unipolar) vs. THA | United Kingdom | 81 | 60+ years with displaced femoral neck fracture, walk >.5 miles living independently | Cognitive difficulty, pathological fracture, osteoarthritis, hip abnormality requiring THA (no bi-lateral, non-index) | 75 63–86 80% | Yes Yes
Blomfeldt, 2007^23^ | Hemi (cemented bipolar) vs. THA | Sweden | 120 | 70 to 90 years, acute displaced femoral neck fracture following a fall, no severe cognitive dysfunction, independent living status, pre- fracture ambulatory with or without aids. | Pathological fracture, fractured more than 48 hours prior, rheumatoid or osteoarthritis | 81 70–90 84% | Yes Yes
Node 2 Displaced – Internal Fixation – Pins/Screws vs. Plate and Screws
Benterud, 1997^24^ | IF - Sliding screw plate plus screw vs. 2 screws | Sweden | 225 | Displaced femoral neck fracture, 70+ years, but younger included | None listed | 81 63–97 79% | No
Madsen, 1987^25^ Linde, 1986^26^ | IF - Sliding screw plate vs. 4 screws | Norway | 103 | Displaced femoral neck fractures | Pathologic fractures, more than 24 hour delay to surgery for Garden stage 4 | 75 25–92 76% | No
Paus, 1986^27^ | IF - Hip compression screw vs. 2 screws | Denmark | 131 | <80 years with displaced femoral neck fractures | None listed | 70 women, 64 men NR 82% | No
Elmerson, 1995^28^ | IF - Sliding screw plate vs. 2 hook pin | Sweden | 248 | Femoral neck fracture | Pathological fractures, unable to reduce fracture | 77 NR, prior to exclusion 50–99 76% | No
Node 1 Displaced – Internal Fixation vs. Hemi vs. Total Hip
Skinner, 1989^29^ Ravikumar, 2000^30^ | IF vs. hemi vs. THA | United Kingdom | 278 | 65+ years with displaced femoral fracture (may not include THA) | None listed | 81 NR 90% | No
Keating, 2006^31^ Keating, 2005^32^ | IF vs. hemi vs. THA (mixed bag) | Scotland | 299 | Mini-mental test score of >6, pre-fracture ability to be mobile independent of another person, no serious concomitant disease (or other clinical reason for exclusion), surgeon determination if treatment options suitable. | Undisplaced or valgus impacted intracapsular fracture. Surgeon decided clinical eligibility and whether to assign to 2 way or 3 way randomization (double counting of patients) | 75 NR, 60+ years 78% | Yes Yes
Rogmark, 2002^33^ Rogmark, 2003^34^ | IF vs. arthro (mixed bag) | Sweden | 409 | 70+ with displaced femoral neck fracture | Confusion, rheumatoid arthritis, bedridden, NH residence | 82 SD 5.8 79% | Yes NR
Node 1 Displaced – Internal Fixation vs. Hemi
El-Abed, 2005^35^ | IF (DHS) vs. uncemented unipolar hemi | Ireland | 122 | 70+ with displaced femoral neck fracture | Non-displaced fractures, pathological fractures, and mental confusion, bedridden. | 73 70–87 67% | Yes Unclear
Davison, 2001^36^ | IF (CHS) vs. hemi, cemented uni and bipolar | United Kingdom | 280 | Age between 65 and 79 years with displaced femoral neck fracture | Cognitive difficulty, pathological fracture, rheumatoid arthritis, long-term steroid therapy | 75 70–78 76% | No
Blomfeldt, 2005^37^ | IF (2 screws) vs. uncemented unipolar hemi | Sweden | 60 | Displaced femoral neck fracture due to fall, 70+ years old, diagnosed dementia and/or severe cognitive dysfunction, mobile with or without aid | Pathological fracture, displaced fractures more than 24 hours, rheumatoid or osteoarthritis, inability to reduce | 84 70–96 90% | No
Roden, 2003^38^ | IF (2 screws) vs. cemented bipolar hemi | Sweden | 100 | 70+, ambulatory, with displaced femoral neck fractures | Medical findings, senility, technical, fracture more than 12 hours previously, irreducible fracture and non- residence | 81 70–96 71% | No
Parker, 2002^39^ Parker, 2000^40^ | IF (3 screws) vs. uncemented unipolar hemi | United Kingdom | 455 | 71+, fit for surgery, with displaced femoral neck fracture | Rheumatoid or osteoarthritis, chronic renal failure, delay to surgery of more than 48 hours, pathological fracture | 82 71–103 80% | No
Puolakka, 2001^41^ | IF (2 screws) vs. cemented hemi (Thompson) | Finland | 32 | 75+ with displaced femoral neck fracture | Unable to walk independently, rheumatoid arthritis | 82 76–90 84% | No
van Dortmont, 2000^42^ | IF (3 screws) vs. cemented hemi (Thompson) | Netherlands | 60 | 70+ patients with GEM diagnosed dementia with displaced fracture | None listed | 84 71–96 87% | No
van Vugt, 1993^43^ | IF (DHS) vs. cemented bipolar hemi | Netherlands | 43 | 71–80 years, displaced femoral neck fracture, with a good degree of independence | None listed | 76 SD 3 58% | No
Node 1 - Displaced – Internal Fixation vs. Total Hip
Johansson, 2006^44^ | IF (2 screws) vs. THA | Sweden | 146 | 75+ years displaced femoral neck fractures, prefracture walking ability | Non-index fracture, contraindications to surgery, malignancy, inflammatory arthritis | 84 75–101 76% | No
Blomfeldt, 2005^45^ | IF (2 screws) vs. THA | Sweden | 102 | Displaced femoral neck fracture, 70+ years, independent living status, ability to walk independently with or without walking aids | Severe mental cognition dysfunction, pathological fracture, more than 24 hours before presentation, or rheumatoid or osteoarthritis | 80 70–96 80% | No
Johansson, 2000^46^ Bachrach- Lindstrom, 2000^47^ Johansson, 2001^48^ | IF (2 screws) vs. THA | Sweden | 100 | 75+, ambulatory prior to displaced femoral neck fracture | No major surgery contraindications, malignancy, rheumatic arthritis (anesthesiologist approval for THA before randomization) | 84 75–101 74% | No
Jonsson, 1996^49^ | IF (2 hook pins) vs. THA | Sweden | 47 | Living in own home, fully ambulatory prefracture | >48 hours at admission, good candidate for THA surgery | 80 67–89 77% | No

Appendix Table E3 Femoral neck evidence-2

Author, Year | Comparison | Patient Focused Outcomes | Assessment (Months) | Loss to Final Followup | Randomization Scheme | Blinded Assessment | Multivariate Adjustments
Node 4 Displaced - Arthroplasty – Hemi Choices
Emery, 1991^10^ | Cement stem vs. not, bipolar hemi | Mortality, pain, use of walking aids, living arrangements | Mean 17 or 18 months (range 12–27 or 12–30) | 26% mortality, no attrition | Randomized card in sealed envelope | No | No
Livesley, 1993^11^ | Ceramic coated vs. not, bipolar hemi | Mortality, complications, residence at 1 year, able to go shopping, functional assessment | 12 | 38% mortality, no attrition | Week of hospital admission | No | No
Node 4 Displaced – Internal Fixation - Cemented vs. Not Cemented Screws
Mattsson, 2006^12^ | IF - Calcium phosphate vs. no c.p. | Pain, walking aid, ADL, muscle strength, mobility scale, range of motion | 6 weeks, 6, 12, 24 | 20% mortality, 21% attrition | Closed envelope system | No | No
Mattson, 2003^13^ | IF - Calcium phosphate vs. no c.p. | No patient outcomes | 1 and 6 weeks | None | Sealed envelope system | No | No
Node 3 Displaced - Arthroplasty – Uni vs. Bipolar Hemi
Raia, 2003^14^ | Uni vs. bipolar hemi (cemented stems) | Musculoskeletal functional assessment: mobility and ADL, SF36, Return to community ambulation | 3, 12 | 21% mortality, 11% attrition | Closed envelope system | No | No
Cornell, 1998^15^ | Uni vs. bipolar hemi (cemented stems) | Range of motion, “get up and go”, 6-minute walk, Johansen hip score | 6 | None | Random generated order, sealed envelopes, opened in operating room | Yes | No
Node 3 Inclusive – Internal Fixation - Hook Pins vs. Screws
Mjorud, 2006^16^ | IF - 2 hook pin vs. 3 screws | Walking ability (short term only), mortality, living situation (incomplete data), re-operation | 4, 12, 24 | 31% mortality, no attrition | Blocked randomization, sealed numbered envelopes | No | No
Lykke, 2003^17^ | IF - 2 hook pin vs. 3 screws | Mortality, discharge to living situation, pain (no data) | 4, 12, 24 | 33% mortality, NR attrition | Computerized random number generation, using numbered, sealed, opaque envelopes in blocks of 50 | No | No
Herngren, 1992^18^ | IF - 2 hook pin vs. 2 screws | Mortality, reoperations/time to complication, need for walking aid, degree of pain | 1, 4, 12 | 18% mortality, 3% attrition | Random numbers sequence | No | No
Olerud, 1991^19^ | IF - 2 hook pin vs. 2 screws | Mortality, reoperations, pain when walking, pain during passive joint motion | 4, 12 | 19% mortality, no attrition | Unclear | No | No
Node 3 Inclusive – Internal Fixation - Screws vs. Screws
Lagerby, 1998^20^ | IF - 2 vs. 3 screws | Mortality, reoperations/time to complication, need for walking aid, degree of pain | 1, 4, 12 | 20% mortality, unclear attrition, at least 10% | Unclear | No | No
Rehnberg, 1989^21^ | IF - 2 vs. 2 screws | Mortality, pain, need for walking aids, living conditions | 4, 12 | 26% mortality, 23% attrition | Random number table | No | No
Node 2 Displaced - Arthroplasty - Hemi vs. Total Hip
Baker, 2006^22^ | Hemi (cemented unipolar) vs. THA | Oxford hip score, walking distance, SF36 | 3, 12, 36 | 10% mortality, 2% attrition | Sealed envelopes | No | No
Blomfeldt, 2007^23^ | Hemi (cemented bipolar) vs. THA | ADL, living condition | 4, 12 | 6% mortality, 2% attrition | Sealed envelope technique | No | No
Node 2 Displaced – Internal Fixation – Pins/Screws vs. Plate and Screws
Benterud, 1997^24^ | IF - Sliding screw plate plus screw vs. 2 screws | Mortality, reoperations/complications | Average 29 (15- 41) or average 27 (13–41) | 26% mortality, unclear attrition | Unclear | No | No
Madsen, 1987^25^ Linde, 1986^26^ | IF - Sliding screw plate vs. 4 screws | Living at home, reoperations | 3, 36 | 26% overall loss | Unclear | No | No
Paus, 1986^27^ | IF - Hip compression screw vs. 2 screws | Mortality, rate of union | 3, 6, 12, 24 | 11% mortality, no attrition | Closed envelope system | No | No
Elmerson, 1995^28^ | IF - Sliding screw plate vs. 2 hook pin | Mortality, failure rate | 6 weeks, 3, 6, 12, 24 | 19% mortality, 4% attrition | Random numbers table | No | No
Node 1 Displaced – Internal Fixation vs. Hemi vs. Total Hip
Skinner, 1989^29^ Ravikumar, 2000^30^ | IF vs. hemi vs. THA | Mortality, pain, loss of prefracture mobility, Harris hip, | 2, 12, follow up at 13 years | Mortality: 25% 1 year, 86% 13 years; Attrition 1 year, NR 13 years | Day of the week | No | No
Keating, 2006^31^ Keating, 2005^32^ | IF vs. hemi vs. THA (mixed bag) | Hip rating questionnaire, EQ-5D, mortality, reoperation (hip outcomes also by >75 years), costs | 4, 12, 24 | 14% mortality, 6% attrition | Allowed surgeon discretion to either 1 of 3 or 1 of 2 randomization options: a centralized, automated computer-based telephone service for randomization, stratified by surgeon with minimization on gender and age | No | Yes
Rogmark, 2002^33^ Rogmark 2003^34^ | IF vs. arthro (mixed bag) | Mortality, failure rate, outcome questionnaire | 4, 12, 24 | 21% mortality, no attrition | Sealed, numbered, opaque envelopes | No | No
Node 1 Displaced – Internal Fixation vs. Hemi
El-Abed, 2005^35^ | IF (DHS) vs. uncemented unipolar hemi | Matta function score, SF36, reoperation, mortality | Minimum of 36 | 22% mortality, NR attrition | Based on admission day | No | No
Davison, 2001^36^ | IF (CHS) vs. hemi, cemented uni and bipolar | Mortality, reoperation, return to pre-injury state, satisfaction, Harris hip score, Barthel home index | 6 weeks, 12, 24, 36, 48, 60 | 23% mortality at 3 years, overall mortality and attrition 61% at 5 years | Computerized random number generation | Yes | No
Blomfeldt, 2005^37^ | IF (2 screws) vs. uncemented unipolar hemi | Failure/reoperation, mortality, Charnley - pain, movement, walking, ADL, EQ-5D, number with hip complications | 4, 12, 24 | 42% mortality, 2% attrition | Sealed envelopes | No | No
Roden, 2003^38^ | IF (2 screws) vs. cemented bipolar hemi | Reoperations, mortality, return to pre-fracture walking, analgesic consumption | 4, 12, 24, 60 | NR | Sealed envelopes | No | No
Parker, 2002^39^ Parker, 2000^40^ | IF (3 screws) vs. uncemented unipolar hemi | Mortality, pain, mobility score, same walking aids, return to residential status, (some by phone, some by clinic visit), reoperations | Minimum of 12, also 24, 36 | Approx 27% mortality, no attrition | Sealed, opaque, identical envelopes | No | No
Puolakka, 2001^41^ | IF (2 screws) vs. cemented hemi (Thompson) | Mortality, reoperations | 24 | 47% mortality, NR attrition | Unclear | No | No
van Dortmont, 2000^42^ | IF (3 screws) vs. cemented hemi (Thompson) | Mortality, wound complication | 4, 12, 24 | 57% 1 year mortality, NR attrition | Unclear | No | No
van Vugt, 1993^43^ | IF (DHS) vs. cemented bipolar hemi | Clinical result score based on secondary intervention, loss of independence, pain, hip mobility score: excellent, good, moderate, poor | 3, 6, 12, 24, 36 | 26% mortality, 2% attrition | Unclear | No | No
Node 1 - Displaced – Internal Fixation vs. Total Hip
Johansson, 2006^44^ | IF (2 screws) vs. THA | Mortality, reoperation/dislocation, dislocation and mortality by mental impairment, Harris hip score, pain (no data) costs | 3, 12, 24 | 29% mortality, 9% attrition | Unclear | No | No
Blomfeldt 2005^45^ Tidermark, 2003^50,51^ | IF (2 screws) vs. THA | Failure/reoperation, mortality, Charnley - pain, movement, walking, ADL, EQ-5D, number with hip complications | 4, 12, 24, 48 | 25% mortality, 5% attrition | Sealed envelopes | No | No
Johansson, 2000^46^ Bachrach- Lindstrom, 2000^47^ Johansson 2001^48^ | IF (2 screws) vs. THA | Mortality, reoperation/complication, Harris hip score, dependence on help by Katz ADL | 3, 12, 24 | 33% mortality, 9% attrition | Sequentially numbered, sealed envelopes | No | No
Jonsson, 1996^49^ | IF (2 hook pins) vs. THA | Use of walking aids, able to do own shopping, walking distance, pain, use of analgesics, home assistance less than 4 hours weekly | 4, 12, 24 | 2% mortality, 26% attrition | Sealed envelopes | No | No

IF = internal fixation, THA = total hip arthroplasty

Appendix Table E4 Intertrochanteric evidence-1

Author, Year | Comparison | Country | N Enrolled | Inclusion | Exclusion | Average Age Range/SD % Female | Power Calculation Met Target
Node 3 Plate/Screw Comparisons - Inclusive
Mattsson, 2005^52^ | EX - DHS with vs. no calcium phosphate cement | Sweden | 112 | 65+ years, ambulatory with or without support, with unstable trochanteric fracture, 65+ years, less than 72 hours between fracture and surgery | Dementia, serious concomitant illness or mental instability, inability to perform functional tests, soft-tissue infection at operation site, cancer, pathological fracture, clotting disorder, corticosteriod treatment >5 mg/day, concurrent or bilateral fracture. | 82 SD 7 or 6.3 81% | Yes Yes
Mattsson, 2004^53^ | EX - DHS with vs. no calcium phosphate cement | Sweden | 26 | Unstable IT fracture, walking without aid/one cane prior to fracture, normal contralateral hip | Senility, pathological fracture, concurrent fractures | 83 66–95 85% | No
Node 3 Plate/Screw Comparisons - Unstable
Moroni, 2004^54^ | EX - DHS with vs. no hydroxy- apatite cement | Italy | 120 | Osteoporosis (by DEXA analysis) with trochanteric fractures | History of previous hip fracture, open fracture, cancer, hard or soft tissue infection at fracture site, multiple fractures, poor positioning of device according to Baumgartner method. | 81 SD 8 or 6 100% | Unclear
Sernbo, 1994^55^ | EX - CHS with vs. without locking lag screw | Sweden | 200 | Trochanteric hip fracture | Fractures older than 5 days, pathological fractures, subtrochanteric fractures | 80 NR 82% | No
Node 3 Intramedullary Nail Comparison - Inclusive
Hardy, 2003^56^ | IM - IMHS (1 screw) static vs. dynamic locking | Belgium | 81 | Fractures with loss of the medial buttress (J-M Type IV – V) or reversed oblique fracture | None stated | 77 SD 11.8 and 13.1 63% | No
Node 2 Intramedullary Nail Comparison – Inclusive
Efstathopoulos, 2007^57^ | IM - Gamma 1 screw vs. Ace Nail 2 screw construct | Greece | 112 | 65+ with Evans-Jensen type I–IV (not specifically stated-determined from exclusion criteria) | Pathological fractures secondary to metastasis, non- ambulatory patients, ASA score V, previous ipsilateral or contralateral hip fractures | 78 69–89 71% | No
Herrera, 2002^58^ | IM - Gamma 1 screw vs. PFN 2 screw | Spain | 250 | Pertrochanteric fractures | None listed | 79 NR 72% | No
Node 2 Plate/Screw Comparisons – Unstable
Lunsjo, 2001^59^ | EX - Medoff (shaft compression) vs. DHS, DHS+TSP, or DCS (by surgeon) | Sweden | 569 | Unstable intertrochanteric fracture | Pathological fractures, previous surgery of the proximal femur, 2-part fractures | 81 42–99 67% | No
Node 2 Plate/Screw Comparisons –Inclusive
Peyser, 2007^60^ | EX - CHS (1 screw) vs. PCCP (2 screw) | Israel | 104 | 60+ with intertrochanteric fracture, amenable to closed reduction | AO/OTA 31.A3, pathological fractures, ipsilateral lower-limb surgery, bi-lateral hip fracture within last 12 months. Failure at closed reduction excluded 11 patients. Unavailable participating surgeons excluded another 7 patients. | 82 62–95 67% | Yes Yes
Kosygan, 2002^61^ | EX - CHS (1 screw) vs. PCCP (2 screw) | United Kingdom | 111 | Extracapsular fracture | Pathological fractures, subtrochanteric fractures or subtroch extension | 83 53–97 81% | No
Janzing, 2002^62^ Brandt, 2002^63^ | EX - DHS (2 screws, some with TSP) vs. PCCP | Belgium | 115 | 60+ years with 31 A1 or A2 pertrochanteric fractures | Severe coxarthrosis of ipsilateral hip, multiple injuries, reverse or bifocal fractures | 83 64–98 NR | No
Olsson, 2001^64^ | EX (CHS) vs. Medoff (shaft compression) | Sweden | 114 | Intertrochanteric fracture of the hip | Earlier surgery of the ipsilateral femur, pathological fractures | 84 61–98 70% | Yes No
Watson, 1998^65^ | EX (CHS) vs. Medoff (shaft compression) | United States | 178 | Adults with acute intertrochanteric fracture | Pathological fracture, previous ipsilateral hip fracture or surgery, congenital or developmental anomaly | 76 25–99 66% | No
Node 2 Intramedullary Nail Comparison – Unstable
Vidyadhara, 2007^66^ | IM - Gamma 1 screw vs. Ace Nail 2 screw construct | India | 73 | 60+ years with unstable trochanteric fracture | Inability to walk before injury; other fractures interfering with rehab; pathological fractures | 69 61–89 49% | No
Schipper, 2004^67^ | IM - Gamma 1 screw vs. PFN 2 screw | Netherlands | 424 | 60+ years with unstable trochanteric fracture, walking ability prior to fracture | Pathological fracture, other fractures interfering with rehabilitation | 82 SD 8.4 or 8 82% | Yes Yes
Fritz, 1999^68^ | IM - Gamma (130°) vs. Gliding Nail (125°) | Germany 80 | | Unstable intertrochanteric fracture | Intracapsular fractures, pathological fractures, coxarthrosis | 82 NR 86% | No
Node 1 Plate/Screw vs. Intramedullary Nail – Inclusive
Hardy, 1998^69^ | EX (CHS) vs. IM (IMHS) | Belgium | 100 | 60+ years with an intertrochanteric fracture that allowed fixture by IHMS or CHS | Pathologic fracture, previous fracture/operation involving the ipsilateral hip, non-index fracture | 81 SD 10.7 or 11.8 77% | No
Baumgaertner, 1998^70^ | EX (CHS plus side plate) vs. IM (IMHS) | United States | 131 | Intertrochanteric fracture | Pathologic fracture | 79 40–99 66% | No
Utrilla, 2005^71^ | EX (CHS) vs. IM (T Gamma) | Spain | 210 | 65+ years with a trochanteric fracture of the femur | Subtrochanteric fractures or subtrochanteric fracture extension, pathologic fractures, history of a previous injury involving the lower limbs, severe concomitant medical condition ASA grade V | 80 65–104 69% | No
Adams, 2001^72^ | EX (CHS) vs. IM (Gamma - 2nd) | United Kingdom | 400 | Intertrochanteric fracture of the hip | Too frail for operation, residence outside hospital region | 81 32–102 78% | No
Park, 1998^73^ | EX (CHS) vs. IM (Gamma AP) | Korea | 60 | Intertrochanteric fractures | None listed | 73 NR 60% | No
Hoffman, 1996^74^ | EX (CHS) vs. IM (Gamma) | New Zealand | 67 | 50+ years with intertrochanteric fracture | Pathologic fracture | 81 SD 10.4 76% | No
Goldhagen, 1994^75^ | EX (CHS) vs. IM (Gamma - 2nd) | United States | 75 | Peritrochanteric fractures | Ipsilateral fracture or surgery of hip, congenital or developmental anomaly, fracture pattern not amenable to treatment by two methods | 78 28–91 69% | No
Aune, 1994^76^ | EX (CHS) vs. IM (Gamma AP) | Norway | 378 | Trochanteric and subtrochanteric fractures | None listed | 81 45–96 59% | No
Ahrengart, 2002^77^ | EX (CHS) vs. IM (Gamma) | Sweden/Finland | 492 | Intertrochanteric fracture | Subtrochanteric fracture, pathologic fracture, previous fracture or operation on same hip, or surgeon unfamiliar with Gamma nail | 80 32–99 72% | No
Butt, 1995^78^ | EX (DHS) vs. IM (Gamma) | United Kingdom | 95 | Peritrochanteric fractures | Not listed | 78 47–101 69% | No
O’Brien, 1995^79^ | EX (DHS) vs. IM (Gamma) | Canada | 101 | Intertrochanteric hip fractures | Fractures more than 1 week old, pathological fractures, subtrochanteric fractures | 77 39–95 74% | No
Pajarinen, 2005^80^ | EX (DHS) vs. IM (PFN) | Finland | 108 | Low-energy extracapsular fracture | Pathological fracture, multiple injuries | 81 SD 9.9 75% | No
Saudan, 2002^81^ | EX (DHS) vs. IM (PFN) | Switzerland | 206 | 55+ years, all AO/OTA Type 31-A1 or A2 fractures caused by a low-energy injury | Pathologic fracture, fractures associated with polytrauma, previous ipsilateral hip or femur surgery, any fracture with extension five centimeters distal to the inferior border of the lesser trochanter. | 83 SD 10 78% | No
Radford, 1993^82^ | EX (DHS) vs. IM (Gamma) | England | 200 | 60+ years with pertrochanteric fractures | None listed | 81 60–97 78% | No
Leung, 1992^83^ | EX (DHS) vs. IM (Gamma) | Hong Kong | 225 | 65+ with pertrochanteric fractures | Purely subtrochanteric fractures | 80 SD 9.46 71% | No
Bridle, 1991^84^ | EX (DHS) vs. IM (Gamma) | England | 100 | 60+ with intertrochnteric fracture | None listed | 82 NR 84% | No
Node 1 Plate/Screw vs. Intramedullary Nail - Unstable
Ekstrom, 2007^85^ | EX (Medoff) vs. IM (PFN) | Sweden | 203 | Adult patients with a closed growth plate and an unstable trochanteric or subtrochanteric fracture | Two-part fracture, high-energy trauma, pathologic fracture, previous surgery of the proximal femur, an intake of daily steroid exceeding 10 mg of prednisolone, ongoing chemotherapy or irradiation treatment due to malignancy, and presence of degenerative osteoarthrosis/arthritis in the injured hip. | 82 48–97 76% | Yes Yes
Miedel, 2005^86^ | EX (Medoff) vs. IM (Gamma) | Sweden | 217 | Acute, unstable trochanteric or subtrochanteric fracture from a simple fall | Pathological fractures, rheumatoid or osteoarthritis, fractures extending more than 5 cm below lesser trochanter | 84 SE 0.6 81% | No
Papasimos, 2005^87^ | EX (DHS) vs. IM (T Gamma, PFN) | Greece | 141 | 60+ years with extracapsular hip fractures | Prefracture inability to walk, pathologic fracture, previous ipsilateral hip or femur surgery, stable trochanteric fractures AO Type 31-A1, fractures with extension 5 cm distal to inferior border of lesser trochanter | 81 NR 61% | No
Pajarinen, 2004^88^ | EX (DHS) vs. IM (PFN) | Finland | 56 | Unstable, low-energy pertrochanteric femoral fractures | Pathological fracture, polytraumatised patients, stable fractures (class A1) and subtrochanteric fractures (class A3) | 79 49–94 80% | No
Sadowski, 2002^89^ | EX (DCS) vs. IM (PFN) | Switzerland | 39 | 55+ years, 31-A3 fractures from low-energy injury | Pathological fractures, fractures from with polytrauma, a preexisting femoral deformity preventing hip screw osteosynthesis or intramedullary nailing, previous surgery on the ipsilateral hip or femur, and fractures extending 5 cm distal to the inferior border of the lesser trochanter | 79 SD 14 69% | No
Harrington, 2002^90^ | EX (CHS) vs. IM (IMHS) | United Kingdom | 102 | 65+ years with unstable intertrochanteric fracture | Dementia and incapable of providing informed consent, pathological fractures, concomitant fractures, previous proximal femoral fracture | 83 SD 8.5 80% | No
Node 1 Internal Fixation vs. Hemiarthroplasty – Unstable
Stappaerts, 1995^91^ | IF (CHS) vs. Endoprosthesis | Belgium | 90 | 70+ years with unstable peritrochanteric fracture | Non-index, arthritis, fractures with subtrochanteric components | 83 70–102 81% | No
Kim, 2005^92^ | IF (PFN) vs. uncemented calcar-replacement bipolar hemi | South Korea | 58 | 75+ unstable comminuted intertroch fracture from low-energy injury | AO/OTA type 31-A1 or A3 fracture | 82 SD 3.3 76% | No
Subtrochanteric Fractures
Lunsjo, 1999^93^ | EX - Medoff (shaft compression) vs. DHS, DHS+TSP, or DCS (by surgeon) | Sweden | 107 | Subtrochanteric fracture | Pathological fracture, previous surgery of proximal femur, factures extending more than 5 cm distal | 80 21–99 80% | No

See Table 2 in the report for more information about included devices

Appendix Table E5 Intertrochanteric evidence-2

Author, Year | Comparison | Subtroch Included/Classification | Patient Focused Outcomes | Assessments (Months) | Loss to Final Followup | Randomization Scheme | Blinded Assessment | Multivariate Adjustments
Node 3 Plate/Screw Comparisons - Inclusive
Mattsson, 2005^52^ | EX - DHS with vs. no calcium phosphate cement | NR E/JM 4 – 5; AO 31 A1, A2 | Pain, SF36, ADLs, strength, walking aids | 1 and 6 weeks, 6 | 4% mortality, 13% attrition | Sealed envelope, randomization stratified by age, gender, pre- fracture mobility | No | No
Mattsson, 2004^53^ | EX - DHS with vs. no calcium phosphate cement | NR AO 31 A2 | No patient outcomes | 1 and 6 weeks, 6 | NR | Closed envelope | No | No
Node 3 Plate/Screw Comparisons - Unstable
Moroni, 2004^54^ | EX - DHS with vs. no hydroxy-apatite cement | NR AO A1, A2 | Harris hip score, SF36 | 6 | Replaced patients lost to followup | Computer generated random number list | No | No
Sernbo, 1994^55^ | EX - CHS with vs. without locking lag screw | Excluded Jensen; Hunter & Krajbick | No patient outcomes | 4 | NR | Sealed envelope | No | No
Node 3 Intramedullary Nail Comparison - Inclusive
Hardy, 2003^56^ | IM - IMHS (1 screw) static vs. dynamic locking | NR E/JM 4–5, reverse oblique | Mortality, mobility score, pain | 1, 3, 6, 12+ | 20% mortality, no attrition | Unclear | No | No
Node 2 Plate/Screw Comparisons -Inclusive
Peyser, 2007^60^ | EX - CHS (1 screw) vs. PCCP (2 screw) | NR AO A1, A2 | Pain, weight-bearing index, mortality | 6 weeks, 3, 6, 12 | NR | Computer generated, random number series, blocked in groups of 10; numbered, sealed, opaque envelopes | No | No
Kosygan, 2002^61^ | EX - CHS (1 screw) vs. PCCP (2 screw) | Excluded E/JM 1–5 | Mortality, complications | 6 weeks, 3, 6 | 15% mortality, no attrition | Sealed envelopes | No | No
Janzing, 2002^62^ Brandt, 2002^63^ | EX - DHS (2 screws, some with TSP) vs. PCCP | NR AO A1, A2 | Mortality, post-op pain, use of walking aids, living situation | 1 week, 3, 6, 12 | 20% mortality, 8% attrition | Sealed envelopes | No | No
Olsson, 2001^64^ | EX (CHS) vs. Medoff (shaft compression) | NR Jensen 1 – 5 | Mortality, complications, residential status, need for walking support | 4 | 14% mortality, 7% attrition | Unseen card draw | No | No
Watson, 1998^65^ | EX (CHS) vs. Medoff (shaft compression) | NR E/JM 1–5 and reverse oblique | (Results by stable/unstable) Ambulation, living situation, pain, mortality, time to union | 1 and 6 weeks, 3, 6, 12 | 10% mortality, 7% attrition | Medical record number | No | No
Node 2 Plate/Screw Comparisons - Unstable
Lunsjo, 2001^59^ | EX - Medoff (shaft compression) vs. DHS, DHS+TSP, or DCS (by surgeon) | NR E/JM 3–5 | Mortality, revision, fixation failure, residential situation, walking ability | 4, 12 | 23% mortality, 8% attrition | Sealed envelopes | No | No
Node 2 Intramedullary Nail Comparison - Inclusive
Efstathopoulos 2007^57^ | IM - Gamma 1 screw vs. Ace Nail 2 screw construct | NR E/JM I – IV | Mortality, mobility (also by stable/not) | 1, 3, 6 | 17% mortality, 4% attrition | Sealed envelopes | No | No
Herrera, 2002^58^ | IM - Gamma 1 screw vs. PFN 2 screw | NR AO A1, A2, A3 | No patient outcomes | 1, 3, 6, 12 | Unclear | Unclear | No | No
Node 2 Intramedullary Nail Comparison - Unstable
Vidyadhara, 2007^66^ | IM - Gamma 1 screw vs. Ace Nail 2 screw construct | NR AO A2, A3 | Harris hip score, pain, limp | 1, 4, 12, 24 | None reported | Computer generated random number table | No | No
Schipper, 2004^67^ | IM - Gamma 1 screw vs. PFN 2 screw | NR AO 31 A2, A3 | Harris hip score, mortality, reoperations, complications | 1, 4, 12 | 21% mortality, 5% attrition | Numbered, blind envelopes, computer generated randomly permutated balanced blocks of 4 and 6 patients, stratified by participating center | No | No
Fritz, 1999^68^ | IM - Gamma (130°) vs. Gliding Nail (125°) | NR AO A2, A3 | Mortality, complications, living situation, Merle d’Aubigne subscale scores | 6 | 13% mortality, 2% attrition | Unclear | No | Yes
Node 1 Plate/Screw vs. Intramedullary Nail - Inclusive
Hardy, 1998^69^ | EX (CHS) vs. IM (IMHS) | NR E/JM 1–5 | Mortality, mobility score, pain, social functioning (some by type of fracture) | 1, 3, 6, 12 | 30% mortality, NR attrition | Medical record number | No | No
Baumgaertner, 1998^70^ | EX (CHS plus side plate) vs. IM (IMHS) | NR Evans/Kyle types I – IV | Mortality, return to pre-fracture living situation, return to pre-fracture mobility, pain (no group data provided) | 6 weeks, 3, 6, 12, 24 | 22% mortality, 0% attrition | Sealed envelopes | No | No
Utrilla, 2005^71^ | EX (CHS) vs. IM (T Gamma) | Excluded E/JM 1–5 | Pain, range of hip flexion, walking ability score, mortality, complications | 1, 3, 6, 12 | 19% mortality, 3% attrition | Sealed envelopes | No | No
Adams, 2001^72^ | EX (CHS) vs. IM (Gamma - 2nd) | NR AO A1, A2, A3, references.r2; E/JM 1–5 | Harris hip score (global), mortality, living in own home, walking independently (1 stick), reoperations, complications | 3, 6, 12 | 30% mortality, 8% attrition | Closed, opaque envelopes | Yes | No
Park, 1998^73^ | EX (CHS) vs. IM (Gamma AP) | NR Tronzo II, III, IV | Time to union, complications, mobility | 3 | NR | Medical record number | No | No
Hoffman, 1996^74^ | EX (CHS) vs. IM (Gamma) | NR E/JM 1–5 | Mobility, mortality, time to union, pain | 6 weeks, 3, 6 | 19% mortality, NR attrition | Computer generated blocked randomization, sealed, opaque numbered envelopes | No | No
Goldhagen, 1994^75^ | EX (CHS) vs. IM (Gamma - 2nd) | Yes Kyle; Seinsheimer | Ambulatory status, range of motion, pain, return to pre- injury functional level | 6 | 4% mortality, 0% attrition | Medical record number | No | No
Aune, 1994^76^ | EX (CHS) vs. IM (Gamma AP) | Yes Jensen; Zickel | Reoperation | Median 17 | NR | Drawing from envelopes | No | No
Ahrengart, 2002^77^ | EX (CHS) vs. IM (Gamma) | Excluded E/JM 1–5 | Pain, use of walking aid, live at home (no outcome descriptions) (only perioperative by fracture stability) | 6 | Unclear | Sealed, numbered envelopes | No | No
Butt, 1995^78^ | EX (DHS) vs. IM (Gamma) | Yes AO (not provided) | No patient outcomes, time to union, complications | Followed until radiologic union | 7% mortality, NR attrition | Week of admission | No | No
O’Brien, 1995^79^ | EX (DHS) vs. IM (Gamma) | Excluded Evans | No patient outcomes | 12 | 7% mortality, NR attrition | Blind envelope selection | No | No
Pajarinen, 2005^80^ | EX (DHS) vs. IM (PFN) | NR AO 31 A1, A2, and "other" | Living situation, recovery to pre- fracture level, walking ability, recover walking to pre-fracture level, mortality | 6 weeks, 4 | 6% mortality, 14% attrition | Unclear | No | No
Saudan, 2002^81^ | EX (DHS) vs. IM (PFN) | Excluded AO 31 A1, A2 | Mortality, complications, reoperations, living situation, pain, social function, mobility score, consolidation | 3, 6, 12 | 14% mortality, 4% attrition | Computer generated randomization | No | No
Radford, 1993^82^ | EX (DHS) vs. IM (Gamma) | NR Evans | No patient outcomes | 3, 12 | NR | Not reported | No | No
Leung, 1992^83^ | EX (DHS) vs. IM (Gamma) | Excluded (subtroch extension included) E/JM 1–5 | Mean time to full weight bearing, mobility, hip range of motion, pain in hip or thigh | 6–12 | 12% mortality, 7% attrition | Sequence of admission | No | No
Bridle, 1991^84^ | EX (DHS) vs. IM (Gamma) | NR Evans | Mobility, mortality, pain, living situation | 6 | 34% mortality, NR attrition | Unclear | No | No
Node 1 Plate/Screw vs. Intramedullary Nail - Unstable
Ekstrom, 2007^85^ | EX (Medoff) vs. IM (PFN) | Yes E/JM 3–5; Seinsheimer 1– 5; AO 31 A2, A3, 32 A1, references.r1 | Mortality, mobility, pain, isometric abductor strength, living situation, union, complications (by inter/sub type) | 6 weeks, 4, 12 | 16% mortality, 25% attrition | Numbered, sealed envelopes, computer generated list, stratified by intertroch/subtroch | No | No
Miedel, 2005^86^ | EX (Medoff) vs. IM (Gamma) | Yes E/JM 3 – 5, Subtroch S2B- C, S3A–B, S4, S5 | (Some results by type of troch/sub) Mortality, revisions, ADL, EQ-5D, Charnley | 4, 12 | 25% mortality, 10% attrition | Sealed envelopes | No | No
Papasimos, 2005^87^ | EX (DHS) vs. IM (T Gamma, PFN) | Excluded AO 31 A2, A3 | Salvati & Wilson hip score, (return to pre- fracture ambulation level and independence - no data), Union | 12 | 7% mortality, 8% attrition | Unclear | No | No
Pajarinen, 2004^88^ | EX (DHS) vs. IM (PFN) | Excluded AO 31A, A2 | No patient outcomes | 6 weeks 4 | 4% mortality, 11% attrition | Unclear | No | No
Sadowski, 2002^89^ | EX (DCS) vs. IM (PFN) | Yes AO 31 A3 | Mortality, complications, reoperations, hip/thigh pain, social function, mobility score, residence | 3, 6, 12 | 8% mortality, 3% attrition | Computer generated random numbers | No | No
Harrington, 2002^90^ | EX (CHS) vs. IM (IMHS) | NR E/JM 3–5 | Ambulation, return to pre-fracture living situation | 3, 5, 12 | 25% mortality, NR attrition | Sealed envelope | Yes | No
Node 1 Internal Fixation vs. Hemiarthroplasty - Unstable
Stappaerts, 1995^91^ | IF (CHS) vs. endoprosthesis | Excluded AO A2; Evans/Jensen 1C–1D | (Restricted to pre- fracture independent patients) Functional capacity | 3 | 17% mortality, NR attrition | Unclear | No | No
Kim, 2005^92^ | IF (PFN) vs. uncemented calcar- replacement bipolar hemi | NR AO A2; E/JM 3 – 4 | Harris hip score, ADL, Mini mental status, ASA, mortality, reoperations/complications | 6 weeks, 3, 6, 12, average 35 | 36% mortality, no attrition | Computer generated random numbers | No | No
Subtrochanteric Fractures
Lunsjo, 1999^93^ | EX - Medoff (shaft compression) vs. DHS, DHS+TSP, or DCS (by surgeon) | Sein-sheimer 1–5 | Mortality, failure, walking aids, living situation | 4, 12 | 15% mortality, 9% attrition | Sealed envelopes | No | No

Appendix Table E6 Femoral neck - categorical pain outcomes from studies with extractable data

Author, Year | Describe Outcome Measure | Group 1 N | % Group 1 with Outcome | Group 2 N | % Group 2 with Outcome | Assessment Period
Node 4 Arthroplasty - Hemi - Cemented vs. Not Cemented
| | | Cement | | None
Emery, 1991^10^ | No pain in hip (no specifics) | 19 | 68% | 20 | 20% | 17 months average
Node 4 Arthroplasty - Hemi - Ceramic Coating vs. No Coating
| None
Node 4 Internal Fixation - Cemented vs. Not Cemented Screws
| None
Node 3 Arthroplasty - Hemi - Unipolar vs. Bipolar (Cemented)
| None
Node 3 Internal Fixation - Screws vs. Screws
| | | Richard | | Uppsala
Lagerby, 1998^20^ | No pain, walk or passive (full group) | 75 | 63% | 86 | 64% | 1 year
Lagerby, 1998^20^ | No pain, walk or passive (not displaced) | 25 | 64% | 30 | 70% | 1 year
Lagerby, 1998^20^ | No pain, walk or passive (displaced) | 50 | 62% | 56 | 61% | 1 year
Node 3 Internal Fixation - Screw vs. Hook Pins
| | | Screw | | Hook pin
Herngren, 1992^18^ | No severe pain, walking or passive | 96 | 89% | 84 | 87% | 4 months
Node 2 Arthroplasty - Hemi vs. Total Hip
| None
Node 2 Internal Fixation – Pins/Screws vs. Sliding Hip Screws
| None
Node 1 Internal Fixation vs. Hemi (Cemented and Not) Arthroplasty
Roden, 2003^38^ | No use of analgesics | 44 | 52% | 44 | 86% | 4 months
Parker, 2002^39^ | Little or no pain, hemi vs. IF | 163 | 56% | 160 | 45% | 1 year
Parker, 2002^39^ | Little or no pain, hemi vs. IF | 105 | 79% | 123 | 72% | 2 years
Parker, 2002^39^ | Little or no pain, hemi vs. IF | 74 | 73% | 91 | 74% | 3 years
Node 1 Internal Fixation vs. Total Hip Arthroplasty
Jonsson, 1996^49^ | No pain walking | 23 | 39% | 24 | 46% | 4 months
Jonsson, 1996^49^ | No pain walking | 23 | 57% | 24 | 33% | 1 year
Jonsson, 1996^49^ | No pain walking | 23 | 57% | 24 | 46% | 2 years
Jonsson, 1996^49^ | No pain walking | 23 | 57% | 24 | 58% | 2 years
Node 1 Internal Fixation vs. Arthroplasty
Rogmark, 2002^33^ | Hip pain: self-report | 162 | 61% | 170 | 34% | 4 months
Rogmark, 2002^33^ | Hip pain: self-report | 116 | 43% | 148 | 25% | 1 year
Rogmark, 2002^33^ | Hip pain: self-report | 84 | 32% | 125 | 25% | 2 years

Appendix Table E7 Femoral neck - continuous pain outcomes from studies with extractable data

Author, Year | Outcome Measure | Group 1 | Mean | SD (Range) | Group 2 N | Mean | SD (Range) | Assessment Period | Estimate
Node 4 Arthroplasty - Hemi - Cemented vs. Not Cemented
| None
Node 4 Arthroplasty - Hemi - Ceramic Coating vs. No Coating
| None
Node 4 Internal Fixation - Cemented vs. Not Cemented Screws
| | Augmented | | | Control
Mattsson, 2006^12^ | VAS, pain with activity | 17 | 9 | 8 | 26 | 7 | 9 | 24 months | NS
Node 4 Internal Fixation - Screws vs. Screws
| | Uppsala | | | vonBahr
Rehnberg, 1989^21^ | Pain (no specifics), 4 point scale | 88 | 1.12 | 0.36 | 77 | 1.4 | 0.59 | 4 months | p <.001
Rehnberg, 1989^21^ | Pain (no specifics), 4 point scale | 64 | 1.02 | 0.12 | 51 | 1.24 | 0.42 | 1 year | p <.01
Node 3 Arthroplasty - Hemi - Unipolar vs. Bipolar (Cemented)
| None
Node 3 Internal Fixation – Screws vs. Hook Pins
| None
Node 2 Arthroplasty - Hemi vs. Total Hip
| | Hemi | | | THA
Blomfeldt, 2007^23^ | Harris hip pain score | 58 | 40 | (20 – 44) | 58 | 42 | (20 – 44) | 4 months | p=0.121
Blomfeldt, 2007^23^ | Harris hip pain score | 55 | 39.1 | (20 – 44) | 56 | 43.1 | (20 – 44) | 1 year | p <.001
Keating, 2006^31^ | Hip rating questionnaire, pain | 62 | 19.4 | 5 | 64 | 19.3 | 4 | 4 months
Keating, 2006^31^ | Hip rating questionnaire, pain | 61 | 21.1 | 4 | 61 | 20.4 | 5 | 1 year
Keating, 2006^31^ | Hip rating questionnaire, pain | 56 | 20.5 | 5 | 59 | 20.9 | 5 | 2 years
Node 2 Internal Fixation – Pins/Screws vs. Sliding Hip Screws
| None
Node 1 Internal Fixation vs. Hemiarthroplasty (Cemented and Not)
Keating, 2006^31^ | Hip rating questionnaire, pain | 111 | 16.8 | 6 | 102 | 19.2 | 5 | 4 months
Keating, 2006^31^ | Hip rating questionnaire, pain | 101 | 18.8 | 6 | 97 | 21 | 4 | 1 year
Keating, 2006^31^ | Hip rating questionnaire, pain | 92 | 19.7 | 6 | 86 | 20.6 | 5 | 2 years
Node 1 Internal Fixation vs. Total Hip
Keating, 2006^31^ | Hip rating questionnaire, pain | 63 | 17.2 | 6 | 64 | 19.3 | 4 | 4 months
Keating, 2006^31^ | Hip rating questionnaire, pain | 61 | 18.7 | 6 | 61 | 20.4 | 5 | 1 year
Keating, 2006^31^ | Hip rating questionnaire, pain | 58 | 19.5 | 6 | 59 | 20.9 | 5 | 2 years

Appendix Table E8 Femoral neck – categorical functional outcomes from studies with extractable data

Author, Year | Outcome Measure | Group 1 N | % Group 1 with Outcome | Group 2 N | % Group 2 with Outcome | Assessment Period
Node 4 Internal Fixation - Cemented vs. Not Cemented Screws
| None | | | | | 2 years
Node 4 Arthroplasty - Hemi - Cemented vs. Not Cemented
| | | Cement | None | None
Emery, 1991^10^ | No walking aids | 19 | 58% | 20 | 20% | 17 months
Emery, 1991^10^ | Living situation, home vs. institution | 19 | 84% | 20 | 75% | 17 months
Node 4 Arthroplasty - Hemi - Ceramic coating vs. No coating
Livesley, 1993^11^ | Able to go shopping | 32 | 41% | 20 | 20% | 1 year
Livesley, 1993^11^ | Living at home | 32 | 59% | 20 | 75% | 1 year
Node 3 Arthroplasty - Hemi - Unipolar vs. Bipolar (cemented)
| | | Unipolar | Bi | Bipolar
Raia, 2003^14^ | Return to community walker | 31 | 74% | 29 | 72% | 1 year
Node 3 Internal Fixation - Screws vs. Screws
| | | Richards | | Uppsala
Laberby, 1998^20^ | No (or 1) walking aid, total | 74 | 47% | 86 | 52% | 1 year
Laberby, 1998^20^ | No (or 1) walking aid, stable | 25 | 48% | 30 | 67% | 1 year
Laberby, 1998^20^ | No (or 1) walking aid, unstable | 49 | 47% | 56 | 45% | 1 year
| | | Uppsala | | vanBahr
Rehnberg, 1989^21^ | Living in own home | 88 | 77% | 77 | 70% | 4 months
Rehnberg, 1989^21^ | Living in own home | 64 | 77% | 51 | 84% | 1 year
Node 3 Internal Fixation – Screw vs. Hook Pins
| | | Screw | | Hook pin
Lykke, 2003^17^ | Return to own home | 72 | 63% | 98 | 60% | 4 month
Lykke, 2003^17^ | Living in NH | 131 | 37% | 147 | 39% | 1 year
Node 2 Arthroplasty - Hemi vs. Total Hip
| | | Hemi | | THA
Blomfeldt, 2007^23^ | Independent living vs. NH status | 58 | 97% | 58 | 93% | 4 months
Blomfeldt, 2007^23^ | Independent living vs. NH status | 55 | 96% | 56 | 96% | 1 year
Node 2 Internal Fixation – Sliding Hip Screws vs. Pins/Screws
| None
Node 1 Internal Fixation vs. Hemi (Cemented and Not)
| | | IF | | THA
Blomfeldt, 2005^37^ | Independent living status | 62 | 11% | 17 | 35% | 2 years
El-Abed, 2005^35^ | Matta score excellent/good | 40 | 42% | 60 | 70% | 3 years
Roden, 2003^38^ | Walk as well as pre-op | 53 | 43% | 44 | 70% | 4 months
Roden, 2003^38^ | Return to original residence | 166 | 85% | 47 | 79%
Parker, 2002^39^ | Use same walking aid | 162 | 37% | 164 | 40% | 1 year
Parker, 2002^39^ | Same residential status | 19 | 83% | 164 | 82% | 1 year
Van Dortmont, 2000^42^ | Retained mobility | 19 | 37% | 17 | 24% | 4 months
Van Dortmont, 2000^42^ | Retained mobility | 18 | 21% | 17 | 18% | 1 year
Node 1 Internal Fixation vs. Total Hip
| | | OR | 95% CI
Jonsson, 1996^49^ | No (or 1) walking aid | 1.5 | | (0.5–5) | | 4 months
Jonsson, 1996^49^ | No (or 1) walking aid | 13 | | (2–88) | | 1 year
Jonsson, 1996^49^ | No (or 1) walking aid | 7.1 | | (1.6–33) | | 2 years
Jonsson, 1996^49^ | Able to do own shopping | 1.7 | | (0.5–6) | | 4 months
Jonsson, 1996^49^ | Able to do own shopping | 4.4 | | (1–20) | | 1 year
Jonsson, 1996^49^ | Able to do own shopping | 2.3 | | (0.6–9) | | 2 years
Jonsson, 1996^49^ | Walk 1 kilometer or more | 2.7 | | (0.8–10) | | 4 months
Jonsson, 1996^49^ | Walk 1 kilometer or more | 1.8 | | (0.4–78) | | 1 year
Jonsson, 1996^49^ | Walk 1 kilometer or more | 1.8 | | (0.5–7) | | 2 years
Node 1 Internal Fixation vs. Arthroplasty
Rogmark,2002^33^ | Need walking aid: self-report | 162 | 66% | 170 | 47% | 4 months
Rogmark,2002^33^ | Need walking aid: self-report | 116 | 53% | 148 | 46% | 1 year
Rogmark,2002^33^ | Need walking aid: self-report | 84 | 54% | 125 | 54% | 2 years
Rogmark,2002^33^ | Reduced mobility: self-report | 162 | 72% | 170 | 44% | 4 months
Rogmark,2002^33^ | Reduced mobility: self-report | 116 | 51% | 148 | 33% | 1 year
Rogmark,2002^33^ | Reduced mobility: self-report | 84 | 36% | 125 | 25% | 2 years

Appendix Table E9 Femoral neck - continuous functional outcomes from studies with extractable data

Author, Year | Outcome Measure | Group 1 N | Mean | SD (Range) | Group 2 N | Mean | SD (Range) | Assessment Period
Node 4 Arthroplasty - Hemi - Cemented vs. Not Cemented
| None
Node 4 Arthroplasty - Hemi - Ceramic Coating vs. No Coating
| None
Node 4 Internal Fixation - Cemented vs. Not Cemented Screws
| None
Node 3 Arthroplasty - Hemi - Unipolar vs. Bipolar (Cemented)
| | Uni | | | Bi
Cornell, 1998^15^ | 6 minute walk (average speed feet/second) | 15 | 1.93 | 0.8 | 33 | 2.67 | ( 0.77–4.86) | 6 months
Cornell, 1998^15^ | Johansen hip score | 15 | 64.9 | 15 | 33 | 63.2 | 15 | 6 months
Node 3 Internal Fixation - Screws vs. Screws
| | Uppsala | | | vonBahr
Rehnberg, 1989^21^ | Need for walking aid | 88 | 1.52 | 0.64 | 77 | 1.96 | 1.35 | 4 months
Rehnberg, 1989^21^ | Need for walking aid | 64 | 1.48 | 0.64 | 51 | 1.7 | 0.66 | 1 year
Node 3 Internal Fixation - Hook Pins vs. Screws
| None
Node 2 Arthroplasty - Hemi vs. Total Hip
| | Hemi | | | THR
Baker, 2006^22^ | Walking distance (miles) | 33 | 1.17 | (0-4) | 36 | 2.23 | (0–25) | 3 years
Baker, 2006^22^ | Oxford Hip Score (global) | 33 | 22.3 | (12–48) | 36 | 18.8 | (12–47) | 3 years
Blomfeldt, 2007^23^ | Harris hip function scores | 58 | 40 | (20–44) | 58 | 42 | (20–44) | 4 months
Blomfeldt, 2007^23^ | Harris hip function scores | 55 | 39.1 | (20–44) | 56 | 43.1 | (20–44) | 1 year
Baker, 2006^22^ | SF36 physical | 33 | 38.1 | (16–58.8) | 36 | 40.53 | (16.2–56.5) | 3 years
Baker, 2006^22^ | SF36 mental | 33 | 55.32 | (39–66.6) | 36 | 52 | (24.2–68.4) | 3 years
Keating, 2006^31^ | EQ-5D, worse health level | 62 | | Adjusted OR | 64 | 1.01 | CI 0.40 – 2.53 | 4 months
Keating, 2006^31^ | EQ-5D, worse health level | 61 | | Adjusted OR | 61 | 1.08 | CI 0.44 – 2.64 | 1 year
Keating, 2006^31^ | EQ-5D, worse health level | 56 | | Adjusted OR | 59 | 0.89 | CI 0.37 – 2.13 | 2 years
Node 2 Internal Fixation - Screws vs. Sliding Hip Screws
| None
Node 1 Internal Fixation vs. Hemi (Cemented and Not)
El-Abed, 2005^35^ | SF-36 mean percentile score. | 62 | 50 | (26–77) | 60 | 74 | (39–90)
Keating, 2006^31^ | EQ-5D, worse health level. | 111 | | Adjusted OR | 102 | 0.45 | CI 0.23 – 0.86 | 4 months
Keating, 2006^31^ | EQ-5D, worse health level. | 101 | | Adjusted OR | 97 | 0.73 | CI 0.38 – 1.41 | 1 year
Keating, 2006^31^ | EQ-5D, worse health level. | 92 | | Adjusted OR | 86 | 1.01 | CI 0.52 – 1.97 | 2 years
Node 1 Internal Fixation vs. Total Hip
Keating, 2006^31^ | EQ-5D, worse health level. | 63 | | Adjusted OR | 64 | 0.49 | CI 0.21 – 1.17 | 4 months
Keating, 2006^31^ | EQ-5D, worse health level. | 61 | | Adjusted OR | 61 | 0.74 | CI 0.32 – 1.74 | 1 year
Keating, 2006^31^ | EQ-5D, worse health level. | 58 | | Adjusted OR | 59 | 0.81 | CI 0.34 – 1.93 | 2 years

Appendix Table E10 Femoral neck mortality

Author, Year | Group 1 N | % Group 1 Mortality | Group 2 N | % Group 2 Mortality | Assessment Period
Node 4 Arthroplasty - Hemi - Cemented vs. Not Cemented
| Cement | | Control
Emery, 1991^10^ | 27 | 7% | 26 | 4% | 3 months
Emery, 1991^10^ | 27 | 30% | 26 | 23% | 17 months average
Node 4 Arthroplasty - Hemi - Ceramic Coating vs. No Coating
| Ceramic | | Control
Livesley, 1993^11^ | 48 | 33% | 34 | 41% | 1 year
Node 4 Internal Fixation - Cemented vs. Not Cemented Screws
| Augmented | | Control
Mattsson, 2006^12^ | 58 | 17% | 60 | 13% | 6 months
Mattsson, 2006^12^ | 58 | 22% | 60 | 17% | 1 year
Node 3 Arthroplasty - Hemi - Unipolar vs. Bipolar (Cemented)
| Uni | | Bi
Raia, 2003^14^ | 60 | 20% | 55 | 22% | 1 year
Cornell, 1998^15^ | 15 | 7% | 33 | 6% | 6 months
Node 3 Internal Fixation - Screws vs. Screws
None
Node 3 Internal Fixation - Hook Pins vs. Screws
| Screw | | Hookpin
Mjorud, 2006^16^ | 101 | 13% | 98 | 13% | 4 months
Mjorud, 2006^16^ | 101 | 19% | 98 | 18% | 1 year
Lykke, 2003^17^ | 131 | 15% | 147 | 10% | 4 months
Lykke, 2003^17^ | 131 | 34% | 147 | 33% | 2 years
Herngren, 1992^18^ | 96 | 22% | 84 | 14% | 1 year
Olerud, 1991^19^ | 59 | 24% | 56 | 14% | 1 year
Node 2 internal Fixation Pins/Screws vs. Sliding Hip Screws
| SHS | | Hookpin
Elmerson, 1995^28^ | 100 | 11% | 122 | 7% | 1 year
Elmerson, 1995^28^ | 52 | 17% | 78 | 19% | 2 years
| SHS | | Screw
Benterud, 1997^24^ | 108 | 10% | 117 | 9% | 3 months
Paus, 1986^27^ | 66 | 8% | 65 | 14% | 18 months average
Node 2 Arthroplasty - Hemi vs. Total
| Hemi | | THA
Baker, 2006^22^ | 41 | 17% | 40 | 8% | 3 years
Blomfeldt, 2007^23^ | 60 | 3% | 60 | 3% | 4 months
Blomfeldt, 2007^23^ | 60 | 5% | 60 | 7% | 1 year
Keating, 2006,^31^ Keating, 2005^32^ | 69 | 13% | 69 | 9% | 2 years
Ravikumar, 2000^30^ | 91 | 15% | 89 | 10% | 2 months
Ravikumar, 2000^30^ | 91 | 27% | 89 | 22% | 1 year
Ravikumar, 2000^30^ | 91 | 86% | 89 | 81% | 13 years
Node 1 Internal Fixation vs. Hemiarthroplasty (Cemented and Not)
Keating, 2006,^31^ Keating, 2005^32^ | 118 | 15% | 111 | 16% | 2 years
El-Abed, 2005^35^ | 62 | 35% | 60 | 20% | 3 years
Blombeldt, 2005^37^ | 30 | 13% | 30 | 17% | 4 months
Blombeldt, 2005^37^ | 30 | 23% | 30 | 33% | 1 year
Blombeldt, 2005^37^ | 30 | 60% | 30 | 43% | 2 years
Roden, 2003^38^ | 53 | 13% | 47 | 9% | 2 years
Roden, 2003^38^ | 53 | 53% | 47 | 43% | 5–6 years
Paulakka, 2001^41^ | 17 | 6% | 15 | 7% | 3 months
Paulakka, 2001^41^ | 17 | 47% | 15 | 47% | 2 years
Parker, 2000^40^ | 102 | 5% | 106 | 7% | 1 months
Parker, 2000^40^ | 102 | 26% | 106 | 29% | 1 year
Parker, 2000^40^ | 102 | 34% | 106 | 40% | 2 years
Parker, 2000^40^ | 102 | 45% | 106 | 58% | 3 years
Ravikumar, 2000^30^ | 91 | 12% | 91 | 15% | 2 months
Ravikumar, 2000^30^ | 91 | 25% | 91 | 27% | 1 year
Ravikumar, 2000^30^ | 91 | 90% | 91 | 86% | 13 years
| IF | | Uni+Bi
Davison, 2001^36^ | 100 | 5% | 200 | 9% | 6 months
Davison, 2001^36^ | 100 | 9% | 200 | 12% | 1 year
Davison, 2001^36^ | 100 | 12% | 200 | 19% | 2 years
Davison, 2001^36^ | 100 | 19% | 200 | 25% | 3 years
Parker, 2000^40^ | 106 | 7% | 102 | 5% | 30 days
Parker, 2000^40^ | 106 | 29% | 102 | 26% | 1 year
Parker, 2000^40^ | 106 | 40% | 102 | 34% | 2 years
Parker, 2000^40^ | 106 | 58% | 102 | 45% | 3 years
Van Dortmont, 2000^42^ | 31 | 35% | 29 | 34% | 4 months
Van Dortmont, 2000^42^ | 31 | 65% | 29 | 48% | 1 year
Van Vugt, 1993^43^ | 21 | 10% | 22 | 23% | 1 year
Van Vugt, 1993^43^ | 21 | 19% | 22 | 23% | 2 years
Node 1 Internal Fixation vs. Total Hip
Keating, 2006,^31^ Keating, 2005^32^ | 69 | 13% | 69 | 9% | 2 years
Blomfeldt, 2005^45^ | 53 | 25% | 49 | 24% | 4 years
Jonsson, 1996^49^ | 23 | 4% | 24 | 0% | 1 month
Ravikumar, 2000^30^ | 91 | 12% | 89 | 10% | 2 months
Ravikumar, 2000^30^ | 91 | 25% | 89 | 22% | 1 year
Ravikumar, 2000^30^ | 91 | 90% | 89 | 81% | 13 years
Node 1 Internal Fixation vs. Arthroplasty
Rogmark, 2002^33^ | 217 | 5% | 192 | 7% | 4 months
| 217 | 12% | 192 | 15% | 1 year
| 217 | 21% | 192 | 21% | 2 years

Appendix Table E11 Intertrochanteric - categorical functional/pain outcomes from studies with extractable data

Outcome Measure (by Node and Comparison) | Author, Year | Group 1 N | % Group 1 with Outcome | Group 2 N | % Group 2 with Outcome | Assessment Period | Subtroch Involvement
Node 3 Plate/Screw Comparisons - Inclusive
None
Node 3 Plate/Screw Comparisons - Unstable
None
Node 3 Intramedullary Nail Comparisons - Inclusive
| | Standard Locking | | Dynamic Locking
Functional thigh pain (no specifics) | Hardy, 2003^56^ | 30 | 20% | 34 | 6% | 1 year | NR
Node 2 Plate/Screw Comparisons - Inclusive
| | SHS | | PCCP
Mobility: walk without help | Janzing, 2002^62^ | 39 | 54% | 44 | 36% | 1 year | NR
Residence: independent | Janzing, 2002^62^ | 39 | 59% | 44 | 45% | 1 year | NR
| | SHS | | MSP
Return to independent walking | Olsson, 2001^64^ | 23 | 26% | 21 | 24% | 4 months | NR
Return to living in own home | Olsson, 2001^64^ | 36 | 69% | 32 | 75% | 4 months | NR
Node 2 Plate/Screw Comparisons - Unstable
| | SHS group | PCCP | MSP
Return to independent walking | Lunsjo, 2001^59^ | 99 | 36% | 105 | 50% | 1 year | NR
Return to living in own home | Lunsjo, 2001^59^ | 140 | 73% | 150 | 77% | 1 year | NR
Node 2 Intramedullary Nail Comparisons - Inclusive
| | Gamma | | Ace TN
Return to pre-fracture mobility | Efstathopoulos, 2007^57^ | 41 | 66% | 47 | 64% | 8 months average | NR
Node 2 Intramedullary Nail Comparisons - Unstable
| | Gamma | | Ace TN
Hip pain (not described) | Vidyadhara, 2007^66^ | 37 | 11% | 36 | 6% | 1 month | NR
Thigh pain (not described) | Vidyadhara, 2007^66^ | 37 | 5% | 36 | 1% | 1 month | NR
Node 1 Plate/Screw vs. Intramedullary Nail - Inclusive
| | SHS | PFN | PFN
Recovery of abilities to pre-op status | Pajarinen, 2005^80^ | 41 | 78% | 42 | 81% | 4 months | NR
Recovery of walking to pre-op status | Pajarinen, 2005^80^ | 41 | 54% | 42 | 76% | 4 months | NR
Walking ability No aids needed | Pajarinen, 2005^80^ | 41 | 29% | 42 | 36% | 4 months | NR
In need of aids, but independent | Pajarinen, 2005^80^ | 41 | 54% | 42 | 57% | 4 months | NR
Residence: own home | Pajarinen, 2005^80^ | 41 | 54% | 42 | 57% | 4 months | NR
Residence: own home | Saudan, 2002^81^ | 89 | 56% | 79 | 47% | 1 year | Excluded
| | SHS | | Gamma
Hip pain (not described) | Utrilla, 2005^71^ | 81 | 54% | 82 | 50% | 1 year | Excluded
Thigh pain (not described) | Utrilla, 2005^71^ | 81 | 56% | 82 | 61% | 1 year | Excluded
Lateral pain over femoral head screw | Ahrengart, 2002^77^ | 179 | 26% | 169 | 27% | 6 months | Excluded
Pain at top of greater trochanter | Ahrengart, 2002^77^ | 179 | 6% | 169 | 20% | 6 months | Excluded
Needs walking aid | Ahrengart, 2002^77^ | 179 | 70% | 169 | 71% | 6 months | Excluded
Lives at home | Ahrengart, 2002^77^ | 179 | 38% | 169 | 65% | 6 months | Excluded
Residence: own home | Adams, 2001^72^ | 121 | 63% | 126 | 60% | 1 year | NR
Walking independently | Adams, 2001^72^ | 121 | 45% | 126 | 44% | 1 year | NR
Walking: no support or 1 stick | Park, 1998^73^ | 30 | 70% | 30 | 80% | 3 months | NR
Resolution of hip pain | Hoffman, 1996^74^ | 31 | 71% | 23 | 61% | 6 months | NR
IT: Community ambulator with or without aid | Goldhagen, 1994^75^ | 34 | 38% | 28 | 36% | 6 months | Included
Sub: Community ambulatory with or without aid | Goldhagen, 1994^75^ | 4 | 50% | 6 | 17% | 6 months | Included
IT: Household ambulator | Goldhagen, 1994^75^ | 34 | 15% | 28 | 21% | 6 months | Included
Sub: Household ambulator | Goldhagen, 1994^75^ | 4 | 50% | 6 | 50% | 6 months | Included
Stable: hip pain | Leung, 1992^83^ | 20 | 25% | 30 | 27% | ~7 months average | Excluded
Unstable: hip pain | Leung, 1992^83^ | 73 | 37% | 63 | 22% | ~7 months average
Stable: thigh pain | Leung, 1992^83^ | 20 | 25% | 30 | 13% | ~7 months average
Unstable: thigh pain | Leung, 1992^83^ | 73 | 4% | 63 | 11% | ~7 months average
Stable: independent mobility | Leung, 1992^83^ | 20 | 40% | 30 | 40% | ~7 months average
Unstable: independent mobility | Leung, 1992^83^ | 73 | 32% | 63 | 35% | ~7 months average
| | SHS | | IMHS
Hip pain, walking | Hardy, 1998^69^ | 35 | 6% | 35 | 6% | 1 year | NR
Thigh pain, walking | Hardy, 1998^69^ | 35 | 6% | 35 | 20% | 1 year | NR
Hip pain (no specifics) | Baumgaertner, 1998^70^ | 52 | 21% | 53 | 28% | Latest followup | NR
Node 1 Plate/Screw vs. Intramedullary Nail - Unstable
| | SHS | | IMHS
Return to previous living status | Harrington, 2002^90^ | 33 | 67% | 30 | 63% | 6 months | NR
| | MSP | | PFN
Walk 15 meters without any aid | Ekstrom, 2007^85^ | 56 | 88% | 64 | 91% | 12 months | Included
Rise from chair without any arm support | Ekstrom, 2007^85^ | 56 | 54% | 64 | 52% | 12 months | Included
Walking aid: none or 1 crutch, | Ekstrom, 2007^85^ | 56 | 38% | 64 | 41% | 12 months | Included
| | DCS | | PFN
Living at home | Sadowski, 2002^89^ | 17 | 29% | 18 | 50% | 1 year | Included
Node 1 Plate/Screw vs. Hemiarthroplasty - Unstable
None
Subtrochanteric
| | | | MSP
Return to walking without aid | Lunsjo, 1999^93^ | 23 | 35% | 30 | | 1 year | Included
Return to own home | Lunsjo, 1999^93^ | 31 | 81% | 36 | | 1 year | Included

Appendix Table E12 Intertrochanteric - continuous functional/pain outcomes from studies with extractable data

Outcome Measure | Author, Year | Group 1 N | Mean | SD (Range) | Group 2 N | Mean | SD (Range) | Assessment Period | Subtroch Involvement
Node 3 Plate/Screw Comparisons - Inclusive
| | | Control | | | HA coated
Harris hip score (global) | Moroni, 2004^54^ | 60 | 63 | 22 | 60 | 70 | 18 | 6 months | NR
SF 36 (global) | Moroni, 2004^54^ | 60 | 56 | 24 | 60 | 62 | 20 | 6 months | NR
Node 3 Plate/Screw Comparisons - Unstable
| | | Control | | | Cement
VAS pain (global) | Mattsson, 2005^52^ | 49 | 28 | 12 | 45 | 14 | 11 | 6 weeks | NR
VAS pain (global) | Mattsson, 2005^52^ | | 9 | 11 | 45 | 7 | 9 | 6 months | NR
VAS functional pain, walking 10 feet | Mattsson, 2005^52^ | 49 | 32 | 15 | 45 | 17 | 10 | 6 weeks | NR
VAS functional pain, walking 10 feet | Mattsson, 2005^52^ | 49 | 11 | 10 | 45 | 7 | 9 | 6 months | NR
VAS functional pain, walking 50 feet | Mattsson, 2005^52^ 49 | 49 | 31 | 17 | 45 | 17 | 12 | 6 weeks | NR
VAS functional pain, walking 50 feet | Mattsson, 2005^52^ | 49 | 12 | 13 | 45 | 7 | 10 | 6 months | NR
Node 3 Intramedullary Nail Comparisons - Inclusive
None
Node 3 Intramedullary Nail Comparisons - Unstable
None
Node 2 Plate/Screw Comparisons - Inclusive
| | | SHS | | | PCCP
VAS pain score (range), single leg stance | Peyser, 2007^60^ | 20 | 5.8 | (0 to 10) | 14 | 3.9 | (0 to 10) | 6 weeks | NR
VAS pain score (range), single leg stance | Peyser, 2007^60^ | 20 | 3.4 | (0 to 7) | 15 | 3.4 | (0 to 7) | 3 months
VAS pain score (range), single leg stance | Peyser, 2007^60^ | 15 | 3.4 | (0 to 10) | 12 | 2.6 | (0 to 6) | 6 months
Node 2 Plate/Screw Comparisons - Unstable
None
Node 2 Intramedullary Nail Comparisons - Inclusive
| | | Gamma | | | Ace TN
Parker mobility score (mean), total | Efstathopoulos, 2007^57^ | 41 | 7 | 2.1 | 47 | 7.1 | 2.5 | 8 months mean | NR
Parker mobility score (mean), unstable | Efstathopoulos, 2007^57^ | 32 | 5.4 | 2.5 | 39 | 5 | 1.9 | 8 months mean | NR
Node 2 Intramedullary Nail Comparisons - Unstable
| | | Gamma | | | Ace
Harris hip score (global) | Vidyadhara, 2007^66^ | 37 | 91 | 2 | 36 | 93 | 3 | 4 months | NR
Harris hip score (global) | Vidyadhara, 2007^66^ | 37 | 95 | 2 | 36 | 96 | 1 | 1 year
Harris hip score (global) | Vidyadhara, 2007^66^ | 37 | 94 | 2 | 36 | 95 | 1 | 2 years
| | | Gamma | (SEM) | | PFN | (SEM)
Harris hip score (global) | Schipper, 2004^67^ | 139 | 53.9 | 1.5 | 140 | 52.6 | 1.5 | 1 months | NR
Harris hip score (global) | Schipper, 2004^67^ | 130 | 62 | 1.7 | 133 | 61.9 | 1.6 | 4 months
Harris hip score (global) | Schipper, 2004^67^ | 64 | 69.5 | 2 | 73 | 66.8 | 2.1 | 1 year
Node 1 Plate/Screw vs. Intramedullary Nail - Inclusive
| | | SHS | | | Gamma
Parker-Palmer scale: Total: walking ability | Utrilla, 2005^71^ | 81 | 6.2 | 2.8 | 82 | 6.4 | 2.8 | 1 year | Excluded
Parker-Palmer scale: Unstable: walking ability | Utrilla, 2005^71^ | 81 | 5.8 | 2.7 | 82 | 7 | 2.1 | 1 year | Excluded
Parker-Palmer scale: Stable: walking ability | Utrilla, 2005^71^ | 81 | 7.3 | 2.4 | 82 | 7.6 | 2.2 | 1 year | Excluded
| | | SHS | | | PFN
Pain: 4 point scale | Saudan, 2002^81^ | 89 | 1.31 | 0.63 | 79 | 1.36 | 0.63 | 1 year | Excluded
Palmer Parker mean mobility score | Saudan, 2002^81^ | 89 | 5.07 | 2.97 | 79 | 4.94 | 3.33 | 1 year | Excluded
Jensen social function (mean) | Saudan, 2002^81^ | 89 | 2.65 | 1.14 | 79 | 2.88 | 1.16 | 1 year | Excluded
| | | SHS | | | IMHS
Parker/Palmer mobility score (global) | Hardy, 1998^69^ | 38 | 3.2 | 3.1 | 37 | 4.6 | 3.1 | 6 months | NR
Parker/Palmer mobility score (global) | Hardy, 1998^69^ | 35 | 3.4 | 3.3 | 35 | 4.8 | 3.2 | 1 year
Node 1 Plate/Screw vs. Intramedullary Nail - Unstable
| | | DCS | PFN
Hip/thigh pain score: 0 none, 4: severe | Sadowski, 2002^89^ | 10 | 1.77 | 0.73 | 18 | 1.44 | 0.86 | 1 year | Included
Jensen social function | Sadowski, 2002^89^ | 10 | 2.5 | 1.3 | 18 | 2.6 | 1 | 1 year | Included
Parker/Palmer score | Sadowski, 2002^89^ | | 6 | 3.5 | 18 | 5 | 2.6 | 1 year | Included
Node 1 Internal Fixation vs. Hemiarthroplasty - Unstable
| | 10 | PFN | | | Hemi
Harris hip score (global) | Kim, 2005#108 | 29 | 80 | 9.7 | 29 | 82 | 12.4 | Latest | NR
Subtrochanteric
None

Appendix Table E13 Intertrochanteric mortality

Author, Year | | Group 1 N | Group 1 % Mortality | Group 2 N | Group 2 % Mortality | Assessment Period | Subtroch Involvement
Node 3 Plate/Screw Comparisons - Inclusive
Moroni, 2004^54^ | NR | | | | | | NR
Sernbo, 1994^94^ | NR | | | | | | Excluded
Node 3 Plate/Screw Comparisons - Unstable
| | Control | | HA
| | | | Cement
Mattsson, 2004^53^ | NR by group | | | | | | NR
Mattsson, 2005^52^ | | 57 | 4% | 55 | 5% | 6 months | NR
Node 3 Intramedullary Device Comparisons - Inclusive
| | Standard | | Dynamic Locking
Hardy, 2003^56^ | | | 13% | 41 | 10% | 3 months | NR
Hardy, 2003^56^ | | | 23% | 41 | 17% | 1 year
Node 2 Plate/Screw Comparisons - Inclusive
| | SHS | | PCCP
Peyser, 2007^60^ | | 53 | 8% | 50 | 4% | 3 months | NR
Peyser, 2007^60^ | | | 15% | 50 | 4% | 6 months
Peyser, 2007^60^ | | | 25% | 50 | 10% | 1 year
Brandt, 2002^63^ | preliminary for 347
Kosygan, 2002^61^ | | 56 | 16% | 52 | 13% | 6 months | Excluded
Janzing, 2002^62^ | | 62 | 19% | 53 | 21% | 1 year | NR
| | SHS | | MSP
Olsson, 2001^64^ | | 60 | 17% | 54 | 11% | 4 months | NR
Watson, 1998^65^ | NR | | | | | | NR
Node 2 Plate/Screw Comparisons - Unstable
| | SHS group
Lunsjo, 2001^95^ | | 301 | 24% | 268 | 22% | 1 year | NR
Node 2 Intramedullary Device Comparisons - Inclusive
Efstathopoulos, 2007^57^ | NR by group | | MSP | | | | NR
Node 2 Intramedullary Device Comparisons - Unstable
Vidyadhara, 2007^66^ | NR | | | | | | NR
| | Gamma | | PFN
Schipper, 2004^67^ | | 213 | 15% | 211 | 18% | 4 months | NR
Schipper, 2004^67^ | | | 20% | 211 | 22% | 1 year
| | Gamma | | Gliding
| | | | Nail
Schipper, 2004^67^ | | 40 | 5% | 40 | 15% | 6 months | NR
Node 1 Plate/Screw vs. Intramedullary devices - Inclusive
| | SHS | | Gamma
Utrilla, 2005^71^ | | 106 | 9% | 104 | 7% | 1 months | Excluded
Utrilla, 2005^71^ | | | 14% | 104 | 8% | 3 months
Utrilla, 2005^71^ | | | 14% | 104 | 11% | 6 months
Utrilla, 2005^71^ | | | 20% | 104 | 18% | 1 year
Ahrengart, 2002^77^ | | 216 | 17% | 210 | 20% | 6 months | Excluded
Adams, 2001^72^ | | 197 | 31% | 203 | 29% | 1 year | NR
Park, 1998^73^ | | | | | | | NR
Hoffman, 1996^74^ | | 36 | 14% | 31 | 26% | 6 months | NR
Butt, 1995^78^ | | 47 | 4% | 48 | 10% | Until satisfactory radiologic union
O’Brien, 1995^79^ | | 49 | 2% | 53 | 11% | 1 month | Excluded
Goldhagen, 1994^75^ | | 40 | 5% | 35 | 3% | 6 months | Included
Aune, 1994^76^ | | | | | | | Included
Radford, 1993^82^ | | 100 | 10% | 100 | 12% | 3 months | NR
Leung, 1992^83^ | | 113 | 13% | 113 | 12% | 6 months | Excluded
Bridle, 1991^84^ | | 51 | 37% | 49 | 31% | 6 months | NR
| | SHS | | PFN
Pajarinen, 2005^80^ | | 54 | 4% | 54 | 7% | 4 months | NR
Saudan, 2002^81^ | | 106 | 12% | 100 | 16% | 1 year | Excluded
| | SHS | | IMHS
Hardy,1998^69^ | | 50 | 26% | 50 | 24% | 6 months | NR
Hardy,1998^69^ | | | 30% | 50 | 30% | 1 year
Baumgaertner, 1998 | | 68 | 26% | 67 | 16% | 1 year | NR
Node 1 Plate/Screw vs. Intramedullary Devices - Unstable
| | MSP | | PFN
Ekstrom, 2007^85^ | Total | 98 | 18% | 105 | 14% | 1 year | Inlcuded
Ekstrom, 2007^85^ | IT | 85 | 18% | 87 | 16% | 1 year
Ekstrom, 2007^85^ | Subtroch | 13 | 23% | 18 | 6% | 1 year
Ekstrom, 2007^85^ | Total | 98 | 6% | 105 | 5% | 4 months
Ekstrom, 2007^85^ | IT | 85 | 6% | 87 | 6% | 4 months
Ekstrom, 2007^85^ | Subtroch | 13 | 8% | 18 | 3% | 4 months
Papasimos, 2005^87^ | NR | | | | | | Excluded
Pajarinen, 2004^88^ | | | | | | | Excluded
| | MSP | | Gamma
Miedel, 2005^86^ | | 108 | 20% | 109 | 10% | 4 months | Included
Miedel, 2005^86^ | | | 29% | 109 | 22% | 1 year
| | DCS | | PFN
Sadowski, 2002^89^ | | 19 | 5% | 20 | 10% | 1 year | Included
| | SHS | | IMHS
Harrington, 2002^90^ | | 52 | 37% | 50 | 40% | 6 months | NR
| 108
Node 1 Internal Fixation vs. Hemiarthroplasty - Unstable
| | PFN | | Hemi
Kim, 2005^92^ | | 29 | 28% | 29 | 14% | 1 year | NR
Kim, 2005^92^ | | | 55% | 29 | 17% | 3 years
Stappaerts, 1995^91^ | NR by group | | | | | | Excluded
Subtrochanteric
| | SHS | | MSP
Lunsjo, 1999^93^ | 29 | 52 | 13% | 55 | 15% | 1 year | Included

## References for Appendix E

(Note that there is a separate set of references at the end of the report and reference numbers are different than those in the appendixes)

1 Karagiannis A, Papakitsou E, Dretakis K, et al. Mortality rates of patients with a hip fracture in a southwestern district of Greece: ten-year follow-up with reference to the type of fracture. Calcified Tissue International. Feb. 2006;78(2):72-7. [pmid: 16467975].
2 Cornwall R, Gilbert MS, Koval KJ, et al. Functional outcomes and mortality vary among different types of hip fractures: a function of patient characteristics. Clinical Orthopaedics & Related Research. Aug. 2004;(425):64-71. [pmid: 15292789].
3 Fox KM, Magaziner J, Hebel JR, et al. Intertrochanteric versus femoral neck hip fractures: differential characteristics, treatment, and sequelae. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. Dec. 1999;54(12):M635-40.
4 Heikkinen T, Willig R, Hanninen A, et al. Hip fractures in Finland--a comparison of patient characteristics and outcomes in six hospitals. Scandinavian Journal of Surgery: SJS. 2004;93(3):234-40. [pmid: 15544081].
5 Hannan EL, Magaziner J, Wang JJ, et al. Mortality and locomotion 6 months after hospitalization for hip fracture: risk factors and risk-adjusted hospital outcomes. JAMA. Jun. 6. 2001;285(21):2736-42. [pmid: 11386929].
6 Koval KJ, Skovron ML, Aharonoff GB, et al. Predictors of functional recovery after hip fracture in the elderly. Clinical Orthopaedics & Related Research. Mar. 1998;(348):22-8. [pmid: 9553529].
7 Koval KJ, Skovron ML, Polatsch D, et al. Dependency after hip fracture in geriatric patients: a study of predictive factors. Journal of Orthopaedic Trauma. 1996;10(8):531-5. [pmid: 8915914].
8 Koval KJ, Skovron ML, Aharonoff GB, et al. Ambulatory ability after hip fracture. A prospective study in geriatric patients. Clinical Orthopaedics & Related Research. Jan. 1995;(310):150-9. [pmid: 7641432].
9 Borgquist L, Nordell E, Lindelow G, et al. Outcome after hip fracture in different health care districts. Rehabilitation of 837 consecutive patients in primary care 1986–88. Scandinavian Journal of Primary Health Care. Dec. 1991;9(4):244-51. [pmid: 1792449].
10 Emery RJ, Broughton NS, Desai K, et al. Bipolar hemiarthroplasty for subcapital fracture of the femoral neck. A prospective randomised trial of cemented Thompson and uncemented Moore stems. Journal of Bone & Joint Surgery - British Volume. Mar. 1991;73(2):322-4.
11 Livesley PJ, Srivastiva VM, Needoff M, et al. Use of a hydroxyapatite-coated hemiarthroplasty in the management of subcapital fractures of the femur. Injury. Apr. 1993;24(4):236-40. [pmid: 8392032].
12 Mattsson P, Larsson S. Calcium phosphate cement for augmentation did not improve results after internal fixation of displaced femoral neck fractures: a randomized study of 118 patients. Acta Orthopaedica. Apr. 2006;77(2):251-6. [pmid: 16752286].
13 Mattsson P, Larsson S. Stability of internally fixed femoral neck fractures augmented with resorbable cement. A prospective randomized study using radiostereometry. Scandinavian Journal of Surgery: SJS. 2003;92(3):215-9. [pmid: 14582545].
14 Raia FJ, Chapman CB, Herrera MF, et al. Unipolar or bipolar hemiarthroplasty for femoral neck fractures in the elderly?. Clinical Orthopaedics & Related Research. Sep. 2003;(414):259-65. [pmid: 12966301].
15 Cornell CN, Levine D, O’Doherty J, et al. Unipolar versus bipolar hemiarthroplasty for the treatment of femoral neck fractures in the elderly.[see comment]. Clinical Orthopaedics & Related Research. Mar. 1998;(348):67-71. [pmid: 9553535].
16 Mjorud J, Skaro O, Solhaug JH, et al. A randomised study in all cervical hip fractures osteosynthesis with Hansson hook-pins versus AO-screws in 199 consecutive patients followed for two years. Injury. Aug. 2006;37(8):768-77. [pmid: 16476431].
17 Lykke N, Lerud PJ, Stromsoe K, et al. Fixation of fractures of the femoral neck. A prospective, randomised trial of three Ullevaal hip screws versus two Hansson hook-pins.[see comment]. Journal of Bone & Joint Surgery - British Volume. Apr. 2003;85(3):426-30.
18 Herngren B, Mork-Petersen F, Bauer M. Uppsala screws or Hansson pins for internal fixation of femoral neck fractures? A prospective study of 180 cases. Acta Orthopaedica Scandinavica. Feb. 1992;63(1):41-6. [pmid: 1738969].
19 Olerud C, Rehnberg L, Hellquist E. Internal fixation of femoral neck fractures. Two methods compared. Journal of Bone & Joint Surgery - British Volume. Jan. 1991;73(1):16-9.
20 Lagerby M, Asplund S, Ringqvist I. Cannulated screws for fixation of femoral neck fractures. No difference between Uppsala screws and Richards screws in a randomized prospective study of 268 cases. Acta Orthopaedica Scandinavica. Aug. 1998;69(4):387-91. [pmid: 9798447].
21 Rehnberg L, Olerud C. Fixation of femoral neck fractures. Comparison of the Uppsala and von Bahr screws. Acta Orthopaedica Scandinavica. Oct. 1989;60(5):579-84. [pmid: 2690558].
22 Baker RP, Squires B, Gargan MF, et al. Total hip arthroplasty and hemiarthroplasty in mobile, independent patients with a displaced intracapsular fracture of the femoral neck. A randomized, controlled trial.[see comment]. Journal of Bone & Joint Surgery - American Volume. Dec. 2006;88(12):2583-9.
23 Blomfeldt R, Tornkvist H, Eriksson K, et al. A randomised controlled trial comparing bipolar hemiarthroplasty with total hip replacement for displaced intracapsular fractures of the femoral neck in elderly patients. Journal of Bone & Joint Surgery - British Volume. Feb. 2007;89(2):160-5.
24 Benterud JG, Husby T, Nordsletten L, et al. Fixation of displaced femoral neck fractures with a sliding screw plate and a cancellous screw or two Olmed screws. A prospective, randomized study of 225 elderly patients with a 3-year follow-up. Annales Chirurgiae et Gynaecologiae. 1997;86(4):338-42. [pmid: 9474428].
25 Madsen F, Linde F, Andersen E, et al. Fixation of displaced femoral neck fractures. A comparison between sliding screw plate and four cancellous bone screws. Acta Orthopaedica Scandinavica. Jun. 1987;58(3):212-6. [pmid: 3307282].
26 Linde F, Andersen E, Hvass I, et al. Avascular femoral head necrosis following fracture fixation. Injury. May. 1986;17(3):159-63. [pmid: 3818052].
27 Paus A, Gjengedal E, Hareide A, et al. Dislocated fractures of the femoral neck treated with von Bahr screws or hip compression screw. Results of a prospective, randomized study. Journal of the Oslo City Hospitals. May-Jun. 1986;36(5–6):55-61. [pmid: 3761061].
28 Elmerson S, Sjostedt A, Zetterberg C. Fixation of femoral neck fracture. A randomized 2-year follow-up study of hook pins and sliding screw plate in 222 patients. Acta Orthopaedica Scandinavica. Dec. 1995;66(6):507-10. [pmid: 8553816].
29 Skinner P, Riley D, Ellery J, et al. Displaced subcapital fractures of the femur: a prospective randomized comparison of internal fixation, hemiarthroplasty and total hip replacement. Injury. Sep. 1989;20(5):291-3. [pmid: 2693355].
30 Ravikumar KJ, Marsh G. Internal fixation versus hemiarthroplasty versus total hip arthroplasty for displaced subcapital fractures of femur--13 year results of a prospective randomised study. Injury. Dec. 2000;31(10):793-7. [pmid: 11154750].
31 Keating JF, Grant A, Masson M, et al. Randomized comparison of reduction and fixation, bipolar hemiarthroplasty, and total hip arthroplasty. Treatment of displaced intracapsular hip fractures in healthy older patients. Journal of Bone & Joint Surgery - American Volume. Feb. 2006;88(2):249-60.
32 Keating JF, Grant A, Masson M, et al. Displaced intracapsular hip fractures in fit, older people: a randomised comparison of reduction and fixation, bipolar hemiarthroplasty and total hip arthroplasty. Health Technology Assessment. Oct. 2005;9(41):iii-iv. ix. x. 1. 65. [pmid: 16202351].
33 Rogmark C, Carlsson A, Johnell O, et al. A prospective randomised trial of internal fixation versus arthroplasty for displaced fractures of the neck of the femur. Functional outcome for 450 patients at two years.[see comment]. Journal of Bone & Joint Surgery - British Volume. Mar. 2002;84(2):183-8.
34 Rogmark C, Carlsson A, Johnell O, et al. Costs of internal fixation and arthroplasty for displaced femoral neck fractures: a randomized study of 68 patients. Acta Orthopaedica Scandinavica. Jun. 2003;74(3):293-8. [pmid: 12899549].
35 El-Abed K, McGuinness A, Brunner J, et al. Comparison of outcomes following uncemented hemiarthroplasty and dynamic hip screw in the treatment of displaced subcapital hip fractures in patients aged greater than 70 years. Acta Orthopaedica Belgica. Feb. 2005;71(1):48-54. [pmid: 15792207].
36 Davison JN, Calder SJ, Anderson GH, et al. Treatment for displaced intracapsular fracture of the proximal femur. A prospective, randomised trial in patients aged 65 to 79 years.[see comment]. Journal of Bone & Joint Surgery - British Volume. Mar. 2001;83(2):206-12.
37 Blomfeldt R, Tornkvist H, Ponzer S, et al. Internal fixation versus hemiarthroplasty for displaced fractures of the femoral neck in elderly patients with severe cognitive impairment.[see comment][erratum appears in J Bone Joint Surg Br. 2005 Aug;87(8):1166]. Journal of Bone & Joint Surgery - British Volume. Apr. 2005;87(4):523-9.
38 Roden M, Schon M, Fredin H. Treatment of displaced femoral neck fractures: a randomized minimum 5-year follow-up study of screws and bipolar hemiprostheses in 100 patients. Acta Orthopaedica Scandinavica. Feb. 2003;74(1):42-4. [pmid: 12635791].
39 Parker MJ, Khan RJK, Crawford J, et al. Hemiarthroplasty versus internal fixation for displaced intracapsular hip fractures in the elderly. A randomised trial of 455 patients. Journal of Bone & Joint Surgery - British Volume. Nov. 2002;84(8):1150-5.
40 Parker MJ, Pryor GA. Internal fixation or arthroplasty for displaced cervical hip fractures in the elderly: a randomised controlled trial of 208 patients. Acta Orthopaedica Scandinavica. Oct. 2000;71(5):440-6. [pmid: 11186397].
41 Puolakka TJ, Laine HJ, Tarvainen T, et al. Thompson hemiarthroplasty is superior to Ullevaal screws in treating displaced femoral neck fractures in patients over 75 years. A prospective randomized study with two-year follow-up. Annales Chirurgiae et Gynaecologiae. 2001;90(3):225-8. [pmid: 11695801].
42 van Dortmont LM, Douw CM, van Breukelen AM, et al. Cannulated screws versus hemiarthroplasty for displaced intracapsular femoral neck fractures in demented patients. Annales Chirurgiae et Gynaecologiae. 2000;89(2):132-7. [pmid: 10905680].
43 van Vugt AB, Oosterwijk WM, Goris RJ. Osteosynthesis versus endoprosthesis in the treatment of unstable intracapsular hip fractures in the elderly. A randomised clinical trial. Archives of Orthopaedic & Trauma Surgery. 1993;113(1):39-45. [pmid: 8117509].
44 Johansson T, Bachrach-Lindstrom M, Aspenberg P, et al. The total costs of a displaced femoral neck fracture: comparison of internal fixation and total hip replacement. A randomised study of 146 hips. International Orthopaedics. Feb. 2006;30(1):1-6. [pmid: 16374651].
45 Blomfeldt R, Tornkvist H, Ponzer S, et al. Comparison of internal fixation with total hip replacement for displaced femoral neck fractures. Randomized, controlled trial performed at four years. Journal of Bone & Joint Surgery - American Volume. Aug. 2005;87(8):1680-8.
46 Johansson T, Jacobsson SA, Ivarsson I, et al. Internal fixation versus total hip arthroplasty in the treatment of displaced femoral neck fractures: a prospective randomized study of 100 hips. Acta Orthopaedica Scandinavica. Dec. 2000;71(6):597-602. [pmid: 11145387].
47 Bachrach-Lindstrom M, Johansson T, Unosson M, et al. Nutritional status and functional capacity after femoral neck fractures: a prospective randomized one-year follow-up study. Aging-Clinical & Experimental Research. Oct. 2000;12(5):366-74.
48 Johansson T, Risto O, Knutsson A, et al. Heterotopic ossification following internal fixation or arthroplasty for displaced femoral neck fractures: a prospective randomized study. International Orthopaedics. 2001;25(4):223-5. [pmid: 11561495].
49 Jonsson B, Sernbo I, Carlsson A, et al. Social function after cervical hip fracture. A comparison of hook-pins and total hip replacement in 47 patients. Acta Orthopaedica Scandinavica. Oct. 1996;67(5):431-4. [pmid: 8948244].
50 Tidermark J. Quality of life and femoral neck fractures. Acta Orthopaedica Scandinavica. Apr. 2003;Supplementum 74(309):1-42. [pmid: 12811943].
51 Tidermark J, Ponzer S, Svensson O, et al. Internal fixation compared with total hip replacement for displaced femoral neck fractures in the elderly. A randomised, controlled trial.[see comment]. Journal of Bone & Joint Surgery - British Volume. Apr. 2003;85(3):380-8.
52 Mattsson P, Alberts A, Dahlberg G, et al. Resorbable cement for the augmentation of internally-fixed unstable trochanteric fractures. A prospective, randomised multicentre study. Journal of Bone & Joint Surgery - British Volume. Sep. 2005;87(9):1203-9.
53 Mattsson P, Larsson S. Unstable trochanteric fractures augmented with calcium phosphate cement. A prospective randomized study using radiostereometry to measure fracture stability. Scandinavian Journal of Surgery: SJS. 2004;93(3):223-8. [pmid: 15544079].
54 Moroni A, Faldini C, Pegreffi F, et al. HA-coated screws decrease the incidence of fixation failure in osteoporotic trochanteric fractures. Clinical Orthopaedics & Related Research. Aug. 2004;(425):87-92. [pmid: 15292792].
55 Sernbo I, Johnell O, Gardsell A. Locking and compression of the lag screw in trochanteric fractures is not beneficial. A prospective, randomized study of 153 cases. Acta Orthopaedica Scandinavica. Feb. 1994;65(1):24-6. [pmid: 8154278].
56 Hardy DCR, Drossos K. Slotted intramedullary hip screw nails reduce proximal mechanical unloading. Clinical Orthopaedics & Related Research. Jan. 2003;(406):176-84. [pmid: 12579017].
57 Efstathopoulos NE, Nikolaou VS, Lazarettos JT. Intramedullary fixation of intertrochanteric hip fractures: a comparison of two implant designs. International Orthopaedics. Feb. 2007;31(1):71-6. [pmid: 16736148].
58 Herrera A, Domingo LJ, Calvo A, et al. A comparative study of trochanteric fractures treated with the Gamma nail or the proximal femoral nail. International Orthopaedics. 2002;26(6):365-9. [pmid: 12466870].
59 Lunsjo K, Ceder L, Thorngren KG, et al. Extramedullary fixation of 569 unstable intertrochanteric fractures: a randomized multicenter trial of the Medoff sliding plate versus three other screw-plate systems. Acta Orthopaedica Scandinavica. Apr. 2001;72(2):133-40. [pmid: 11372943].
60 Peyser A, Weil YA, Brocke L, et al. A prospective, randomised study comparing the percutaneous compression plate and the compression hip screw for the treatment of intertrochanteric fractures of the hip. Journal of Bone & Joint Surgery - British Volume. Sep. 2007;89(9):1210-7.
61 Kosygan KP, Mohan R, Newman RJ. The Gotfried percutaneous compression plate compared with the conventional classic hip screw for the fixation of intertrochanteric fractures of the hip.[see comment]. Journal of Bone & Joint Surgery - British Volume. Jan. 2002;84(1):19-22.
62 Janzing HMJ, Houben BJJ, Brandt SE, et al. The Gotfried PerCutaneous Compression Plate versus the Dynamic Hip Screw in the treatment of pertrochanteric hip fractures: minimal invasive treatment reduces operative time and postoperative pain. Journal of Trauma-Injury Infection & Critical Care. Feb. 2002;52(2):293-8.
63 Brandt SE, Lefever S, Janzing HMJ, et al. Percutaneous compression plating (PCCP) versus the dynamic hip screw for pertrochanteric hip fractures: preliminary results. Injury. Jun. 2002;33(5):413-8. [pmid: 12095721].
64 Olsson O, Ceder L, Hauggaard A. Femoral shortening in intertrochanteric fractures. A comparison between the Medoff sliding plate and the compression hip screw. Journal of Bone & Joint Surgery - British Volume. May. 2001;83(4):572-8.
65 Watson JT, Moed BR, Cramer KE, et al. Comparison of the compression hip screw with the Medoff sliding plate for intertrochanteric fractures. Clinical Orthopaedics & Related Research. Mar. 1998;(348):79-86. [pmid: 9553537].
66 Vidyadhara S, Rao SK. One and two femoral neck screws with intramedullary nails for unstable trochanteric fractures of femur in the elderly--randomised clinical trial. Injury. Jul. 2007;38(7):806-14. [pmid: 17049347].
67 Schipper IB, Steyerberg EW, Castelein RM, et al. Treatment of unstable trochanteric fractures. Randomised comparison of the gamma nail and the proximal femoral nail. Journal of Bone & Joint Surgery - British Volume. Jan. 2004;86(1):86-94.
68 Fritz T, Hiersemann K, Krieglstein C, et al. Prospective randomized comparison of gliding nail and gamma nail in the therapy of trochanteric fractures. Archives of Orthopaedic & Trauma Surgery. 1999;119(1–2):1-6. [pmid: 10076936].
69 Hardy DC, Descamps PY, Krallis P, et al. Use of an intramedullary hip-screw compared with a compression hip-screw with a plate for intertrochanteric femoral fractures. A prospective, randomized study of one hundred patients.[see comment]. Journal of Bone & Joint Surgery - American Volume. May. 1998;80(5):618-30.
70 Baumgaertner MR, Curtin SL, Lindskog DM. Intramedullary versus extramedullary fixation for the treatment of intertrochanteric hip fractures. Clinical Orthopaedics & Related Research. Mar. 1998;(348):87-94. [pmid: 9553538].
71 Utrilla AL, Reig JS, Munoz FM, et al. Trochanteric gamma nail and compression hip screw for trochanteric fractures: a randomized, prospective, comparative study in 210 elderly patients with a new design of the gamma nail. Journal of Orthopaedic Trauma. Apr. 2005;19(4):229-33. [pmid: 15795570].
72 Adams CI, Robinson CM, Court-Brown CM, et al. Prospective randomized controlled trial of an intramedullary nail versus dynamic screw and plate for intertrochanteric fractures of the femur.[see comment]. Journal of Orthopaedic Trauma. Aug. 2001;15(6):394-400. [pmid: 11514765].
73 Park SR, Kang JS, Kim HS, et al. Treatment of intertrochanteric fracture with the Gamma AP locking nail or by a compression hip screw--a randomised prospective trial. International Orthopaedics. 1998;22(3):157-60. [pmid: 9728307].
74 Hoffman CW, Lynskey TG. Intertrochanteric fractures of the femur: a randomized prospective comparison of the Gamma nail and the Ambi hip screw. Australian & New Zealand Journal of Surgery. Mar. 1996;66(3):151-5. [pmid: 8639131].
75 Goldhagen PR, O’Connor DR, Schwarze D, et al. A prospective comparative study of the compression hip screw and the gamma nail. Journal of Orthopaedic Trauma. Oct. 1994;8(5):367-72. [pmid: 7996318].
76 Aune AK, Ekeland A, Odegaard B, et al. Gamma nail vs compression screw for trochanteric femoral fractures. 15 reoperations in a prospective, randomized study of 378 patients. Acta Orthopaedica Scandinavica. Apr. 1994;65(2):127-30. [pmid: 8197841].
77 Ahrengart L, Tornkvist H, Fornander P, et al. A randomized study of the compression hip screw and Gamma nail in 426 fractures. Clinical Orthopaedics & Related Research. Aug. 2002;(401):209-22. [pmid: 12151898].
78 Butt MS, Krikler SJ, Nafie S, et al. Comparison of dynamic hip screw and gamma nail: a prospective, randomized, controlled trial. Injury. Nov. 1995;26(9):615-8. [pmid: 8550169].
79 O’Brien PJ, Meek RN, Blachut PA, et al. Fixation of intertrochanteric hip fractures: gamma nail versus dynamic hip screw. A randomized, prospective study. Canadian Journal of Surgery. Dec. 1995;38(6):516-20.
80 Pajarinen J, Lindahl J, Michelsson O, et al. Pertrochanteric femoral fractures treated with a dynamic hip screw or a proximal femoral nail. A randomised study comparing post-operative rehabilitation. Journal of Bone & Joint Surgery - British Volume. Jan. 2005;87(1):76-81.
81 Saudan M, Lubbeke A, Sadowski C, et al. Pertrochanteric fractures: is there an advantage to an intramedullary nail?: a randomized, prospective study of 206 patients comparing the dynamic hip screw and proximal femoral nail. Journal of Orthopaedic Trauma. Jul. 2002;16(6):386-93. [pmid: 12142826].
82 Radford PJ, Needoff M, Webb JK. A prospective randomised comparison of the dynamic hip screw and the gamma locking nail. Journal of Bone & Joint Surgery - British Volume. Sep. 1993;75(5):789-93.
83 Leung KS, So WS, Shen WY, et al. Gamma nails and dynamic hip screws for peritrochanteric fractures. A randomised prospective study in elderly patients. Journal of Bone & Joint Surgery - British Volume. May. 1992;74(3):345-51.
84 Bridle SH, Patel AD, Bircher M, et al. Fixation of intertrochanteric fractures of the femur. A randomised prospective comparison of the gamma nail and the dynamic hip screw. Journal of Bone & Joint Surgery - British Volume. Mar. 1991;73(2):330-4.
85 Ekstrom W, Karlsson-Thur C, Larsson S, et al. Functional outcome in treatment of unstable trochanteric and subtrochanteric fractures with the proximal femoral nail and the Medoff sliding plate. Journal of Orthopaedic Trauma. Jan. 2007;21(1):18-25. [pmid: 17211264].
86 Miedel R, Ponzer S, Tornkvist H, et al. The standard Gamma nail or the Medoff sliding plate for unstable trochanteric and subtrochanteric fractures. A randomised, controlled trial. Journal of Bone & Joint Surgery - British Volume. Jan. 2005;87(1):68-75.
87 Papasimos S, Koutsojannis CM, Panagopoulos A, et al. A randomised comparison of AMBI, TGN and PFN for treatment of unstable trochanteric fractures. Archives of Orthopaedic & Trauma Surgery. Sep. 2005;125(7):462-8. [pmid: 16059696].
88 Pajarinen J, Lindahl J, Savolainen V, et al. Femoral shaft medialisation and neck-shaft angle in unstable pertrochanteric femoral fractures. International Orthopaedics. Dec. 2004;28(6):347-53. [pmid: 15597171].
89 Sadowski C, Lubbeke A, Saudan M, et al. Treatment of reverse oblique and transverse intertrochanteric fractures with use of an intramedullary nail or a 95 degrees screw-plate: a prospective, randomized study. Journal of Bone & Joint Surgery - American Volume. Mar. 2002;84-A(3):372-81.
90 Harrington P, Nihal A, Singhania AK, et al. Intramedullary hip screw versus sliding hip screw for unstable intertrochanteric femoral fractures in the elderly. Injury. Jan. 2002;33(1):23-8. [pmid: 11879828].
91 Stappaerts KH, Deldycke J, Broos PL, et al. Treatment of unstable peritrochanteric fractures in elderly patients with a compression hip screw or with the Vandeputte (VDP) endoprosthesis: a prospective randomized study.[see comment]. Journal of Orthopaedic Trauma. 1995;9(4):292-7. [pmid: 7562150].
92 Kim S-Y, Kim Y-G, Hwang J-K. Cementless calcar-replacement hemiarthroplasty compared with intramedullary fixation of unstable intertrochanteric fractures. A prospective, randomized study. Journal of Bone & Joint Surgery - American Volume. Oct. 2005;87(10):2186-92.
93 Lunsjo K, Ceder L, Tidermark J, et al. Extramedullary fixation of 107 subtrochanteric fractures: a randomized multicenter trial of the Medoff sliding plate versus 3 other screw-plate systems. Acta Orthopaedica Scandinavica. Oct. 1999;70(5):459-66. [pmid: 10622478].
94 Sernbo I, Holmquist H, Redlund-Johnell I, et al. Radiographic prediction of failure after fixation of cervical hip fracture. Acta Orthopaedica Scandinavica. Jun. 1994;65(3):295-8. [pmid: 8042481].
95 Lunsjo K, Ceder L, Stigsson L, et al. One-way compression along the femoral shaft with the Medoff sliding plate. The first European experience of 104 intertrochanteric fractures with a 1-year follow-up. Acta Orthopaedica Scandinavica. Aug. 1995;66(4):343-6. [pmid: 7676823].