# Search Strings

Search string for hip fracture literature:

- 1. ((hip$ or femur$ or femoral$ or $capsular$ or $trochant$) adj4 fracture$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
- 2. limit 1 to yr="1985 – 2008", English language, humans

Search string for device-related literature:

- 3. (pin$1 or nail$ or screw$1 or plate$1 or arthroplast$ or fix$ or prosthes$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]

Search for RCTs

- 4. 2 and 3
- 5. (randomized controlled trial or clinical trial).pt.
- 6. (randomized controlled trials or random allocation or double blind method or single blind method).sh.
- 7. 5 or 6
- 8. clinical trial.pt.
- 9. exp Clinical Trial/
- 10. (clin$ adj25 trial$).ti,ab.
- 11. ((singl$ or doubl$ or trebl$ or trip$) adj25 (blind$ or mask$)).ti,ab.
- 12. (research design or placebos).sh.
- 13. (placebo$ or random$).ti,ab.
- 14. 8 or 9 or 10 or 11 or 12 or 13
- 15. 7 or 14
- 16. 4 and 15

Search for observational literature

- 17. Cohort studies/ or comparative study/ or follow-up studies/ or prospective studies/ or risk factors/ or cohort.mp. or compared.mp. or groups.mp. or multivariate.mp.
- 18. 2 and 17
- 19. limit 18 to not (comment or editorial or historical article or interview or letter)
- 20 limit 19 to (addresses or bibliography or biography or classical article or clinical
- 21 "United States"/ep [Epidemiology]
- 22. 4 and 21
- 23. recovery.mp.
- 24. 4 and 23
- 25. odds ratio
- 26. 4 and 25