# Technical Expert Panel

Michael Baumgaertner, MD | Yale University School of Medicine New Haven, CT
Ken Koval, MD | Dartmouth Hitchcock Medical Center Lebanon, NH
Hans Kreder, MD | Sunnybrook Health Sciences Center Toronto, Ontario
Jay Magaziner, MD | University of Maryland at Baltimore Baltimore, MD
Mark Sokolowski, MD | Trinity Orthopaedics, SC Oak Park, IL
Charles Turkelson, PhD | American Academy of Orthopaedic Surgeons Rosemont, IL