# Previously Published Systematic Reviews and Meta-analysis

First Author, Year | Title Fracture Pattern Patient Population | # of Studies Patient N Hip N | Devices | Outcomes Addressed | Reported Results
Femoral Neck: Displaced/Not Displaced
Bhandari, 2003^1^ Searched 1969 to 2002 | Internal fixation compared with arthroplasty for displaced fractures of the femoral neck | 14 RCTs N=1,933 | Internal fixation (plate-screw or screw only) vs. arthroplasty, (hemi and THA) | Mortality, pain, good function (based on independent ADLs), revisions, infections, blood loss, time in surgery | Arthroplasty for displaced femoral neck fracture reduces risk of revision, but has greater infection rates, blood loss, operative time, and possibly increase in early mortality rates. No differences in pain or function. Larger trials needed. Hemiarthroplasty and THA populations pooled for analysis.
Rogmark, 2006^2^ Searched 1966 to 2004 | Primary arthroplasty is better than internal fixation of displaced femoral neck fractures | 14 RCTs N=2,289 | Internal fixation (plate-screw or screw only) vs. arthroplasty, (hemi and THA) | Mortality, reoperations, major method-related complications | Update of Bhandari, 2003 review. Recommended THA for healthy, lucid 70–80 year old and hemi for older, impaired, or institutionalized patients based on reoperations and complications.
Parker, 1998^3^ Search period NR | Choice of implant for internal fixation of femoral neck fractures Displaced and not displaced | 25 RCTs N=4,925 | Multiple IF devices | No final patient outcomes. Overall complication rate | Screws superior to pins. No advantage to side-plate. Not able to determine optimum number or types of screws.
Varley, 2004^4^ Searched “last 40 years” | Stability of hip hemiarthroplasties Femoral neck fractures, subtypes not specified | 133 RCTs to case series N=23,107 | Unipolar, bipolar hemis | No patient final outcomes. Dislocations of prosthesis | Overall dislocation rate was 3.4%. No difference in dislocation rate between uni and bipolar hemiarthroplasties if account for posterior surgical approach and use of cement. Increased risk of open reduction of dislocations for bipolar.
Parker, 2006^5^ Searched 1966 to 2005 | Internal fixation versus arthroplasty for intracapsular proximal femoral fractures in adults Both displaced and undisplaced | 17 RCTs N=2,694 patients N=2,697 hips | Devices not specified; internal fixation, hemiarthroplasty, total arthroplasty | Operative details, complications related to type of surgery, post-op complications, post-op care outcomes, anatomical restoration, mortality, pain, residence at final followup, mobility, HRQoL | Internal fixation has less initial operative trauma, but increased risk of reoperations. There still exists a need for studies which define which devices best serve different patient groups.
Parker, 2001^6^ Searched 1966 to 2003 | Internal fixation implants for intracapsular proximal femoral fractures in adults Both displaced and undisplaced | 28 RCTs and quasi experimental N=5,547 patients N=5,552 hips | 22 devices; nails, pins, screws, plates | Primary: non-union rate. Other: operative details, fracture fixation failures, post-op complications, anatomical restoration, mortality, pain, residence at final followup, mobility, regain of ADLs, HRQoL | Inconclusive. Sliding hip screw took longer to insert, with increased blood loss, compared to multiple screws or pins.
Khan, 2002^7^ Search period NR | Cemented or uncemented hemiarthroplasty for displaced intracapsular fractures of the hip - a systematic review | 18 RCTs to comparative N=NR | Unipolar and bipolar hemis | Pain, mobility, mortality, revision rate, blood loss, time in surgery | Tend to support use of cement for displaced fractures. Radiographic differences were variable and frequently did not correlate with clinical outcomes.
Parker, 2006^8^ Searched up to Dec 2005 | Arthroplasties (with and without bone cement) for proximal femoral fractures in adults | 17 RCTs N=1,920 | Unipolar and bipolar hemis, THA | Operative details, complications related to type of surgery, post-op complications, post-op care outcomes, anatomical restoration, mortality, pain, residence at final followup, mobility, HRQoL | Limited evidence that cementing a prosthesis may reduce post-op pain and improve mobility. Insufficient evidence for the roles of bipolar and total hip arthroplasty.
Miyomoto, 2008^9^ Search period NR | Surgical management of hip fractures: an evidence based review of the literature for femoral neck fractures | 35 RCTs to retrospective comparisons N=NR | Multiple forms of IF and arthroplasty | Complications, union, mortality, pain, functional outcomes, perioperative outcomes | No clear evidence for any one IF procedure. Some evidence for bipolar superior to unipolar, but may not justify cost. Less pain with cementing. THA for cognitively intact is well supported, especially compared to IF.
Extracapsular/Stable and Unstable Intertrochanteric and Subtrochanteric
Chinoy, 1999^10^ Search period NR | Fixed nail plates versus sliding hip systems for the treatment of trochanteric femoral fractures: a meta analysis of 14 studies Stable or unstable intertrochanteric, and mixed fractures | 14 RCTs to Comparative studies N=2,855 patients | Jewett, Thornton fixed nail, McLaughlin, or sliding hip screw | Cut-out, non-union, total complications, implant breakage, reoperation, mortality, pain, mobility | Sliding hip screw superior to fixed nail plates. (Many articles too old for inclusion in current review. Jewett and McLaughlin nails not included devices in current review.)
Schipper, 2004^11^ Searched 1990 - present | Unstable trochanteric femoral fractures: extramedullary or intramedullary fixation. | 18 RCTs N=2,326 | SHS, Gamma nail, IMHS, Static Nail, PFN, Gliding Nail | Failure rate, reoperation, other non-patient outcomes | Intramedullary implants biomechanically superior for unstable fractures. SHS is a safe and simple alternative for stable fractures. Evidence for either treatment class is still incomplete.
Audige, 2003^12^ Searched up to Dec 2002 | Implant-related complications in the treatment of unstable intertrochanteric fractures: meta- analysis of dynamic screw-plate versus dynamic screw- intramedullary nail devices | 17 RCTs N=2,431 | Dynamic screw intramedullary devices vs. dynamic screw- plate devices | No final patient outcomes. Device complications, iatrogenic fractures | No differences in frequency of implant- related complications; DSIN tended to have less cut-outs, but persistent, if rare, risk of iatrogenic fracture.
Jones, 2006^13^ Searched up to June 2004 | Are short femoral nails superior to the sliding hip screw? A met- analysis of 24 studies Stable, unstable, and subtrochanteric fractures | 24 RCTs N=3,202 N=3,279 | IMN, SHS | No final patient outcomes. Failure rate, reoperations, cut-out, fracture healing complications | Total failure rate and reoperation rate were greater for femoral nails. No evidence of reduced failure rate for nails in unstable tranchanteric fractures.
Kregor, 2005^14^ Searched 1996 – 2004 | Unstable pertrochanteric femoral fractures. 31-A3 fractures | 8 studies, RCT to case series | IMN, 95 plate, SHS, and SHS with TSP | Union rates, reoperation, mobility | Failure rates for SHS are too high for recommendation. More trials needed to compare IMN to 95 plate.
Parker, 1996^15^ Search period NR | Gamma vs. DHS nailing for extracapsular femoral fractures Trochanteric and subtrochanteric fractures. | 10 RCTs N=1,794 N=1,797 | Gamma nail vs. DHS | Mortality, reoperations, infection, iatrogenic fracture, cut-out | Gamma nail had increased risk of fracture of femoral shaft and reoperation rate. Not recommended until fracture problem is resolved. Larger trials needed.
Parker, 2006^16^ Searched up to Dec 2005 | Replacement arthroplasty versus internal fixation for extracapsular hip fractures in adults Unstable intertrochanteric fractures, 70+ yrs | 2 RCTs N=148 | Hemi, PFN, CHS | Operative details, device complications, post-op complications, anatomical restoration, mortality, loss of independent status, Harris hip score | Insufficient evidence for replacement arthroplasty vs. internal fixation for extracapsular hip fractures. Larger, well- designed trials needed.
Parker, 2006^17^ Searched up to March 2006 | Intramedullary nails for extracapsular hip fractures in adults Stable and unstable | 6 RCTs and quasi N=1,071 | PFN, Gliding Nail, Gamma Nail | Operative details, fracture fixation complications, post-op complications, anatomical restoration, early and long term mortality, pain, mobility, failure to return to living at home | Insufficient evidence for whether different IMN designs for extracapsular hip fractures matter. Ranking designs is not a priority given the evidence superiority for sliding hip screws over IMNs.
Parker, 2000^18^ Searched up to Sept 2004 | Condylocephalic nails vs. extramedullary implants for extracapsular hip fractures | 11 RCTs and quasi N=1,667 | 7 devices 2 intramedullary nails, 5 extramedullary implants | Operative details, fracture fixation complications, post-op complications, anatomical restoration, early and long-term mortality, pain, mobility, failure to return to living at home | Use of condylocephalic nails (Ender nails) is not supported due to increase in fracture healing complications, reoperation rate, residual pain, limb deformity, compared to extramedullary implant.
Parker, 2004^19^ Searched up to June 2005 | Gamma and other cephalocondylic intramedullary nails vs. extramedullary implants for extracapsular hip fractures in adults Stable and unstable trochanteric and subtrochanteric | 32 RCTs and quasi N=5,116 patients N=5,118 hips | 7 devices; 5 intramedullary nails, 2 extramedullary implants | Operative details, fracture fixation complications, post-op complications, anatomical restoration, mortality, pain, mobility, failure to return to pre- fracture residential status | Sliding hip screw superior for trochanteric fractures compared to intramedullary nails. Further research required if intramedullary nails have advantages for other fracture types or if different intramedullary nails produce similar results.
Parker, 2006^20^ Searched up to July 2005 | Extramedullary fixation implants and external fixators for extracapsular hip fractures in adults Unstable intertrochanteric, subtrochanteric Adults | 14 RCTs N=2,222 patients | 7 devices, fixed nail plates, various sliding hip screws, and others | Operative details, fracture fixation complications, post-op complications, anatomical restoration, mortality, pain, failure to return home, mobility and function | Sliding hip screw is superior to fixed nail plated due to increased fixation failure. Other comparisons were inconclusive.
Kaplan, 2008^21^ Search period NR | Evidence-based review of literature for surgical treatment of intertrochanteric fractures Stable and unstable fractures Adults | 25 RCTs retrospective comparative N=NR | Multiple IMN, extramedullary fixation, hemi, THA | Complications, union, mortality, functional outcomes | Neither plate/screw fixation nor IM are superior for stable fractures. Unstable fractures theoretically would benefit from IM, but insufficient evidence to support recommendation. Comminuted fracture in osteoporotic bone can be treated with arthroplasty in select patients.

ADL – Activities of daily living

CHS – Compression hip screw

DHS – Dynamic hip screw

IF – Internal fixation

IMN – Intramedullary nail

IMHS – Intramedullary hip screw

NR – Not reported

PFN – Proximal femoral nail

RCT – Randomized controlled trial

SHS – Sliding hip screw

THA – Total hip arthroplasty

TSP – Trochanteric stabilizing plate

## References for Appendix A

(Note that there is a separate set of references at the end of the report and reference numbers are different than those in the appendixes)

1 Bhandari M, Devereaux PJ, Swiontkowski MF, et al. Internal fixation compared with arthroplasty for displaced fractures of the femoral neck. A meta-analysis. Journal of Bone & Joint Surgery - American Volume. Sep. 2003;85-A(9):1673-81.
2 Rogmark C, Johnell O. Primary arthroplasty is better than internal fixation of displaced femoral neck fractures: a meta-analysis of 14 randomized studies with 2,289 patients.[see comment]. Acta Orthopaedica. Jun. 2006;77(3):359-67. [pmid: 16819672].
3 Parker MJ, Blundell C. Choice of implant for internal fixation of femoral neck fractures. Meta-analysis of 25 randomised trials including 4,925 patients. Acta Orthopaedica Scandinavica. Apr. 1998;69(2):138-43. [pmid: 9602770].
4 Varley J, Parker MJ. Stability of hip hemiarthroplasties. International Orthopaedics. Oct. 2004;28(5):274-7. [pmid: 15316673].
5 Parker MJ, Gurusamy K. Internal fixation versus arthroplasty for intracapsular proximal femoral fractures in adults.[update of Cochrane Database Syst Rev. 2003;(2):CD001708; PMID: 12804413]. Cochrane Database of Systematic Reviews. 2006;(4):CD001708. [pmid: 17054139].
6 Parker MJ, Stockton G. Internal fixation implants for intracapsular proximal femoral fractures in adults. Cochrane Database of Systematic Reviews. 2001;(4):CD001467. [pmid: 11687113].
7 Khan RJK, MacDowell A, Crossman P, et al. Cemented or uncemented hemiarthroplasty for displaced intracapsular fractures of the hip--a systematic review. Injury. Jan. 2002;33(1):13-7. [pmid: 11879826].
8 Parker MJ, Gurusamy K. Arthroplasties (with and without bone cement) for proximal femoral fractures in adults.[update of Cochrane Database Syst Rev. 2004;(2):CD001706; PMID: 15106159]. Cochrane Database of Systematic Reviews. 2006;3:CD001706. [pmid: 16855974].
9 Miyamoto RG, Kaplan KM, Levine BR, et al. Surgical management of hip fractures: an evidence-based review of the literature. I: femoral neck fractures. Journal of the American Academy of Orthopaedic Surgeons. Oct. 2008;16(10):596-607. [pmid: 18832603].
10 Chinoy MA, Parker MJ. Fixed nail plates versus sliding hip systems for the treatment of trochanteric femoral fractures: a meta analysis of 14 studies. Injury. Apr. 1999;30(3):157-63. [pmid: 10476259].
11 Schipper IB, Marti RK, van der Werken C. Unstable trochanteric femoral fractures: extramedullary or intramedullary fixation. Review of literature. Injury. Feb. 2004;35(2):142-51. [pmid: 14736471].
12 Audige L, Hanson B, Swiontkowski MF. Implant-related complications in the treatment of unstable intertrochanteric fractures: meta-analysis of dynamic screw-plate versus dynamic screw-intramedullary nail devices.[see comment]. International Orthopaedics. 2003;27(4):197-203. [pmid: 12734684].
13 Jones HW, Johnston P, Parker M. Are short femoral nails superior to the sliding hip screw? A meta-analysis of 24 studies involving 3,279 fractures. International Orthopaedics. Apr. 2006;30(2):69-78. [pmid: 16496147].
14 Kregor PJ, Obremskey WT, Kreder HJ, et al. Unstable pertrochanteric femoral fractures. Journal of Orthopaedic Trauma. Jan. 2005;19(1):63-6. [pmid: 15668589].
15 Parker MJ, Pryor GA. Gamma versus DHS nailing for extracapsular femoral fractures. Meta-analysis of ten randomised trials. International Orthopaedics. 1996;20(3):163-8. [pmid: 8832319].
16 Parker MJ, Handoll HHG. Replacement arthroplasty versus internal fixation for extracapsular hip fractures in adults.[update of Cochrane Database Syst Rev. 2000;(2):CD000086; PMID: 10796293]. Cochrane Database of Systematic Reviews. 2006;(2):CD000086. [pmid: 16625528].
17 Parker MJ, Handoll HHG. Intramedullary nails for extracapsular hip fractures in adults.[update of Cochrane Database Syst Rev. 2005;(2):CD004961; PMID: 15846737]. Cochrane Database of Systematic Reviews. 2006;3:CD004961. [pmid: 16856070].
18 Parker MJ, Handoll HH, Bhonsle S, et al. Condylocephalic nails versus extramedullary implants for extracapsular hip fractures. Cochrane Database of Systematic Reviews. 2000;(2):CD000338. [pmid: 10796346].
19 Parker MJ, Handoll HHG. Gamma and other cephalocondylic intramedullary nails versus extramedullary implants for extracapsular hip fractures.[update in Cochrane Database Syst Rev. 2005;(4):CD000093; PMID: 16235272][update of Cochrane Database Syst Rev. 2002;(4):CD000093; PMID: 12519535]. Cochrane Database of Systematic Reviews. 2004;(1):CD000093. [pmid: 14973946].
20 Parker MJ, Handoll HHG. Extramedullary fixation implants and external fixators for extracapsular hip fractures in adults.[update of Cochrane Database Syst Rev. 2002;(4):CD000339; PMID: 12519541]. Cochrane Database of Systematic Reviews. 2006;(1):CD000339. [pmid: 16437422].
21 Kaplan K, Miyamoto R, Levine BR, et al. Surgical management of hip fractures: an evidence-based review of the literature. II: intertrochanteric fractures. Journal of the American Academy of Orthopaedic Surgeons. Nov. 2008;16(11):665-73. [pmid: 18978289].