# List of Acronyms/Abbreviations

ADL: Activities of daily living
AHRQ: Agency for Healthcare Research and Quality
AO/OTA: Arbeitsgemeinschaft fur Osteosynthesefragen (Association for the Study of Internal Fixation)/Orthopedic Trauma Association
ASA: American Society of Anesthesiologists
BMI: Body mass index
CI: Confidence interval
EPC: Evidence-based practice center
FDA: Food and Drug Administration
FN: Femoral neck
GRADE: Grading of Recommendations Assessment, Development, and Evaluation
IADL: Independent activities of daily living
IF: Internal fixation
IM: Intramedullary device
IMHS: Intramedullary hip screws
IMN: Intramedullary nails
IT: Intertrochanteric
NH: Nursing home
NR: Not reported
QoL: Quality of life
RCT: Randomized controlled trial
RR: Relative risk
SHS: Sliding hip screws
SRS: Systematic review software
ST: Subtrochanteric
TEP: Technical expert panel
THA: Total hip arthroplasty
TSP: Trochanteric stabilizing plate
VAS: Visual analog score