# Results

## Literature Search Results

The original MEDLINE® and Cochrane Central database search for primary studies yielded 15,621 citations of EAR outcomes and 194 citations of UL outcomes. The update search for primary studies published between September, 2008 and April, 2009 yielded 918 citations We identified 654 of these as potentially relevant and retrieved the full-text articles for further evaluation. Of these, 478 did not meet eligibility criteria (Appendix E); thus, a total of 165 primary study articles met the inclusion criteria and were included in this report (Figure 5). Of the 165 primary study articles, 60 were randomized controlled trials (RCTs), 3 were nonrandomized comparative studies, and 102 were observational studies (either cohort or nested case-control studies). The publication dates of the 165 primary study articles ranged from 1980 to 2009.

Figure 5 Literature flow in this report

The MEDLINE®, Cochrane Database of Systemic Reviews, and the Health Technology Assessments database search for systematic reviews yielded 1746 citations. We identified 68 of these as potentially relevant and retrieved the full-text articles for further evaluation. Of these, 46 did not meet eligibility criteria. After examining the 22 qualifying systematic reviews, 11 were excluded for various reasons (Appendix D; Figure 5).

The grand overview tables (Tables 1, 2, and 3) detailed how many studies reported an outcome (either as a primary or secondary outcome) that is of interest and also listed the total number of unique studies (including those from systematic reviews) as each study may have provided data for more than one outcome.

Table 1 Number of primary studies on vitamin D intake or concentration and specific health outcomes that could be applicable to certain life stages

| Growth | CVD clinical | Body weight (adults) | Total cancer | Prostate cancer | Colorectal cancer | Colorectal adenoma | Breast cancer | Breast mammographic density | Pancreatic cancer | Immune function clinical outcomes | Preeclampsia & pregnancy outcomes | All-cause mortality | Bone health clinical outcomes | Bone mineral density or content | Hypertension | Blood pressure
0–6 mo | 8
7 mo–2 y | 1 | | | | | | | | | | 1^B^
3–8 y
9–18 y | 2 | | | | | | | | | | | | | | 2
19–50 y | | 1 | 1 | 1 | 2 | 1 | | 1 | | | 1 | | | | 1 | 1 | 1
51–70 y | | 3 | 2 | 1 | 10 | 6 | 1 | 2 | | 2 | 1 | | 8 | | 1 | 1 | 1
≥71 y | | 2 | | 1 | | 1 | | | | | 1 | | 8 | 3 | | 1 | 2
Pregnant & lactating women | 7 | | | | | | | | | | 1 | 1
Postmenopause | | 1 | 1 | 1 | | 1 | | | | | 1^B^ | | | | | 1 | 2
Total unique studies per outcome | 9 | 5 | 3 | 3 | 12 | 9 | 1 | 3 | 0 | 2 | 2 | 1 | 8 | 3 | 3 | 2 C | 3
[Total number of RCTs per outcome] | [6] | [1] | [3 A ] | [2] | [0] | [1] | [0] | [0] | 0 | [0] | [0] | [0] | [8] | [3] | [3 A ] | [0] | [3 A ]
Systematic reviews (unique studies) per outcome | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 1 | | 0 | 0
| 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | (4) | (73) | | 0 | 0

Shaded cells indicate that either the eligibility criteria excluded outcomes in those life stages or the outcomes are not applicable to those life stages. Blank unshaded cells indicate no primary studies were identified in this report in those life stages.

A Only RCTs were eligible for this outcome

B Relationship between maternal 25(OH)D concentration and atopic eczema in infants

C 1 study was a combined analysis of Nurses Health Study and Health Professionals Follow-up Study

Table 2 Number of primary studies on calcium intake and specific health outcomes that could be applicable to certain life stages

| Growth | CVD clinical | Body weight (adults) | Total cancer | Prostate cancer | Colorectal cancer | Colorectal adenoma | Breast cancer | Breast mammographic density | Pancreatic cancer | Immune function clinical outcomes | Preeclampsia & pregnancy outcomes | All-cause mortality | Bone health clinical outcomes | Bone mineral density or content | Hypertension | Blood pressure
0–6 mo | 1
7 mo–2 y
3–8 y | 1 | | | | | 1^B^
9–18 y | 3
19–50 y | | 2 | 3 | 1 | | 3 | | 1 | 1 | 1 | | | 1 | | | 5 | 3
51 – 70 y | | 9 | 5 | 1 | 12 | 17 | 6 | 5 | | 2 | | | 1 | | | 4 | 2
≥71 y | | 1 | 1 | 1 | | 1^B^ | | | | 1 | | | | | | | 2
Pregnant & lactating women | 1 | | | | | | | | | | | 14
Postmenopause | | 1 | 4 | 1 | | | | 4 | | | | | | | | 1 | 2
Total unique studies per outcome [Total number of RCTs per outcome] | 3 | 11 | 8 | 3 | 12 | 21 | 6 | 6 | 1 | 2 C | 0 | 14 | 1 | | | 5 D | 5
| [1] | [0] | [8 A ] | [2] | [0] | [0] | [1] | [0] | [0] | [0] | 0 | 14 | 1 | | | [0] | [5 A ]
Systematic reviews (unique studies) per outcome | 1 | 0 | 3 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 0 | 1 | 0 | | | 0 | 6
| (17) | 0 | (41) | 0 | 0 | (2) | (2) | 0 | 0 | 0 | 0 | (12) | 0 | | | 0 | (64)

Shaded cells indicate that either the eligibility criteria excluded outcomes in those life stages or the outcomes are not applicable to those life stages. Blank unshaded cells indicate no primary studies were identified in this report in those life stages.

A Only RCTs were eligible for this outcome

B Association between total calcium intake in childhood and colorectal cancer after 65 years of followup

C 1 study was a combined analysis of Nurses Health Study and Health Professionals Follow-up Study

D 6 analyses, including 2 separate analyses of NHANES I

Table 3 Number of primary studies on combined vitamin D and calcium intake and specific health outcomes that are relevant to certain life stages

| Growth | CVD clinical | Body weight (adults) | Total cancer | Prostate cancer | Colorectal cancer | Colorectal adenoma | Breast cancer | Breast mammographic density | Pancreatic cancer | Immune function clinical outcomes | Preeclampsia & pregnancy outcomes | All-cause mortality | Bone health clinical outcomes | Bone mineral density or content | Hypertension | Blood pressure
0–6 mo | 1
7 mo–2 y
3–8 y
9–18 y | | | | | | | | | | | | | | | 1
19–50 y | | | 1 | | | | | | | | | | | 1 | | | 1
51–70 y | | 1 | 1 | | | | 1 | | | | | | 3 | | | 1 | 1
≥71 y | | | 1 | | | | | | | | | | 8
Pregnant & lactating women | 1 | | | | | | | | | | | 1
Postmenopause | | 1 | 1 | 2 | | 1 | 1 | 1 | | | | | 8 | 1 | 3 | 1 | 1
Total unique studies per outcome [Total number of RCTs per outcome] | 1 | 1^B^ [1] | 2^B^ [2^A^] | 2^B^ [2] | 0 | 1^B^ [1] | 2^B^ [1] | 1^B^ [1] | 0 | 0 | 0 | 1 | 11^B,C^ [11] | 2^B^ [2] | 4 [4 A ] | 1^B^ [1] | 2^B^ [2^A^]
Systematic reviews (unique studies) per outcome | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (10 B ) | 1 (119 B ) | | 0 | 0

Shaded cells indicate that either the eligibility criteria excluded outcomes in those life stages or the outcomes are not applicable to those life stages. Blank unshaded cells indicate no primary studies were identified in this report in those life stages.

A Only RCTs were eligible for this outcome

B Including the Women’s Health Initiative (WHI) trial

C A de novo reanalysis of the 10 RCTs in a previous systematic review and one newly added trial

## Vitamin D and Health Outcomes

### Vitamin D and Growth

We reviewed primary studies that evaluated relationships between vitamin D and growth parameters in infants and children.

Synopsis

Seven intervention studies and two observational studies evaluated intake of or exposure to vitamin D and growth parameters in infants and children. Two intervention studies from the same center found a significant association of maternal vitamin D intakes with infant birth weights. Study methodologies were incompletely reported in these two studies. The rest of the studies did not find a significant association between either maternal or offspring vitamin D intake and offspring’s weight or height. No overall conclusions could be drawn as the studies reviewed had diverse populations and methodological approaches.

Detailed presentation

(Tables 4, 5, 6 & 7)

Table 4 Vitamin D on growth outcome: Characteristics of interventional studies

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
RCTs
Maxwell 1981^38^ Brooke 1980^34^ UK (51°N) [6793058] [6989438] | - Health status; - Mean age (range/SD), y; - Male (%) | pregnancy nd 0 | 25(OH)D at 28–32 wk: 20.1 nmol/L | Vit D 1000 IU/d 3^rd^ trimester only | nd | First generation Asian immigrants only
Feliciano 1994^36^ China (22°N to 47°N) [8078115] | - Health status; - Mean age (range/SD), y; - Male (%) | healthy term newborn nd | 86% infant breastfed until 5–6 mo | Vit D 100 IU/d vs. 200 IU/d vs. 400 IU/d | nd
El-Hajj 2006^35^ Lebanon (33°N) [16278262] | - Health status; - Mean age (range/SD), y; - Male (%) | healthy 13.2 (10–17) 0 | 25(OH)D 35 nmol/L; dietary Ca 677 mg/d | Vit D_3_ 200 IU/d vs. 2000 IU/d vs. placebo x 1 y | 98% in placebo; 98% in low dose; 97% in high dose | 7.4 h sun exposure/wk
Wagner 2006^39^ Charleston, US (32°N) [17661565] | - Health status; - Mean age (range/SD), y; - Male (%) | Fully lactating; 1 mo postpartum 29 0 | Lactating mother’s dietary Vit D 273 IU/d; dietary calcium intake: 1125 mg/d; | Mother Vit D_3_ 400 IU/d + infant 300 IU/d vs. mother 6400 IU/d + infant 0 IU/d | ≥80% in mothers; as low as 61% for infants | 78% white; 11% black; 11% Hispanic
Marya 1988^37^ India (28°N) [3243609] | - Health status; - Mean age (range/SD), y; - Male (%) | no pregnancy-related complications 24 0 | Expectant mother’s dietary Vit D 35 IU/d; calcium 429 mg/d | Mother Vit D 1.2 mil IU (total; 600,000 IU vit D2 in 7^th^ & 8^th^ mo) vs. no supplement | nd
Mallet 1986^40^ France (48° N) [3755517] | - Health status; - Mean age (range/SD), y; - Male (%) | pregnancy newborn nd | Ca intake 550 to1000 mg/d in 55% of the subjects | Vit D 1000 IU/d vs. 200,000 IU 1x dose | nd
Nonrandomized comparative study
Marya 1981^41^ India (28°N) [7239350] | - Health status; - Mean age (range/SD), y; - Male (%) | no pregnancy-related complications nd 0 | Expectant mother’s daily milk intake <500 mL; dietary Vit D <30 IU/d | Vit D 1200 IU/d + Ca 375 mg/d (3^rd^ trimester) or Vit D 1.2 mil IU (total; 600,000 IU in 7^th^ & 8^th^ mo) or no supplement | nd

Table 5 Vitamin D and growth outcomes: Characteristics of cohort studies

Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV exposure | Lifestyle | Comments
Morley 2006^43^ Australia (38°S) [16352684] | - Health status; - Mean age (range/SD), y; - Male (%) | singleton pregnancy; no disease 29 0 | Assay methodSeason blood drawn | RIA winter & summer | Length and weight in offspring stratified by mother’s 25(OH)D | | X | X | | X | X | 99% white; excluded dark skin or women with concealing clothing
Gale 2008^42^ PAHSG UK (50°N) [17311057] | - Health status; - Mean age (range/SD), y; - Male (%) | singleton pregnancy 17 wk 26.3 0 | Assay methodSeason blood drawn | RIA nd | Length and weight in offspring stratified by mother’s 25(OH)D | | X | | | X | | White only

Table 6 Vitamin D and growth outcomes: Results of RCTs

Author Year Study Name [PMID] | Life Stage | Outcome | 1°/2° | Mean Followup | Interventions, Daily Dose | No. Analyzed | Unit | Baseline | Change (SD) | Change 95% Cl | Net Diff | Net Diff 95% Cl | P Btw | Study Quality
Maxwell 1981^38^ Brooke 1980^34^ [6793058] [6989438] | Pregnant women & infant 0–6 mo (Asians) | Infant birth weight | 2° | until delivery | Vit D 1000 IU | 59 | g | NA | Final 3157 | 3037, 3277 | Diff + 123 | −50, 296^C^ | NS | B
Maxwell 1981^38^ Brooke 1980^34^ [6793058] [6989438] | Pregnant women & infant 0–6 mo (Asians) | Infant birth weight | 2° | until delivery | Control | 67 | | NA | 3034 | 2909, 3159 | | | | B
Maxwell 1981^38^ Brooke 1980^34^ [6793058] [6989438] | Pregnant women & infant 0–6 mo (Asians) | Infant birth length | 2° | until delivery | Vit D 1000 IU | 59 | cm | NA | Final 49.7 | 49.6, 49.8 | Diff + 0.2 | 0.1, 0.3^C^ | NS | B
Maxwell 1981^38^ Brooke 1980^34^ [6793058] [6989438] | Pregnant women & infant 0–6 mo (Asians) | Infant birth length | 2° | until delivery | Control | 67 | | NA | 49.5 | 49.4, 49.6 | | | | B
Feliciano 1994^36^ [8078115] | 0–6 mo | Weight gain born in spring, N. China^A^ | 1° | 6 mo | Vit D 400 IU | 12 | g | nd | 3745 | 2613, 4877 | −463 | −1852, 926^C^ | NS | C
Feliciano 1994^36^ [8078115] | 0–6 mo | Weight gain born in spring, N. China^A^ | 1° | 6 mo | Vit D 200 IU | 13 | | nd | 5296 | 4718, 5874 | 1088 | 96, 2080^C^ | NS | C
Feliciano 1994^36^ [8078115] | 0–6 mo | Weight gain born in spring, N. China^A^ | 1° | 6 mo | Vit D 100 IU | 17 | | nd | 4208 | 3402, 5013 | | | | C
Feliciano 1994^36^ [8078115] | 0–6 mo | Length gain born in spring, N. China | 1° | 6 mo | Vit D 400 IU | 12 | cm | nd | 18.8 | 17.4, 20.2 | −0.5 | −2.7, 1.7^C^ | NS | C
Feliciano 1994^36^ [8078115] | 0–6 mo | Length gain born in spring, N. China | 1° | 6 mo | Vit D 200 IU | 13 | | nd | 19.0 | 18.1, 19.9 | −0.3 | −2.2, 1.6^C^ | NS | C
Feliciano 1994^36^ [8078115] | 0–6 mo | Length gain born in spring, N. China | 1° | 6 mo | Vit D 100 IU | 15 | | nd | 19.3 | 17.6, 21.0 | | | | C
El-Hajj 2006^35^ [16278262] | 9–18 y female, premenarche | Height | 2° | 1 y | Vit D_3_ 2000 IU | nd, ≤34 total | % | nd | 5.6% | ~4.8, 6.4^C^ | ~1.8% | ~0.6, 3.0^C^ | 0.07 | C
El-Hajj 2006^35^ [16278262] | 9–18 y female, premenarche | Height | 2° | 1 y | Vit D_3_ 200 IU | nd, ≤34 total | | nd | 5.0% | ~4.2, 5.8^C^ | ~1.2% | ~−0.01, 2.4^C^ | 0.07 | C
El-Hajj 2006^35^ [16278262] | 9–18 y female, premenarche | Height | 2° | 1 y | Placebo | nd, ≤34 total | | nd | 3.8% | ~0.9, 6.7^C^ | | | 0.07 | C
El-Hajj 2006^35^ [16278262] | 9–18 y female, premenarche | Weight | 2° | 1 y | Vit D_3_ 2000 IU | nd, ≤34 total | % | nd | 18.4% | ~14.7, 22.1^C^ | ~3.5% | ~−1.3, 8.3^C^ | 0.25 | C
El-Hajj 2006^35^ [16278262] | 9–18 y female, premenarche | Weight | 2° | 1 y | Vit D_3_ 200 IU | nd, ≤34 total | | nd | 15.3% | ~12.5, 18.1^C^ | ~0.4 | −3.7, 4.5^C^ | 0.25 | C
El-Hajj 2006^35^ [16278262] | 9–18 y female, premenarche | Weight | 2° | 1 y | Placebo | nd, ≤34 total | | nd | 14.9% | ~11.8, 18.0^C^ | | | 0.25 | C
Wagner 2006^39^ [17661565] | Lactating mothers & infant 0–6 mo; 7 mo - 2 y | Infant weight^B^ | 1° | 7 mo | Mother (400) +infant (300) | 10 | g | NA | Final 7600 | 7100, 8100 | Diff −800 | −2300, 700^C^ | 0.30 | C
Wagner 2006^39^ [17661565] | Lactating mothers & infant 0–6 mo; 7 mo - 2 y | Infant weight^B^ | 1° | 7 mo | Mother (6400) +infant (0) | 9 | | NA | 8400 | 7700, 9100 | | | | C
Wagner 2006^39^ [17661565] | Lactating mothers & infant 0–6 mo; 7 mo - 2 y | Infant length | 1° | 7 mo | Mother (400) +infant (300) | 10 | cm | NA | Final 65.5 | 64.4, 66.6 | Diff −3.8 | −7.8, 0.2^C^ | 0.06 | C
Wagner 2006^39^ [17661565] | Lactating mothers & infant 0–6 mo; 7 mo - 2 y | Infant length | 1° | 7 mo | Mother (6400) +infant (0) | 9 | | NA | 69.3 | 67.4, 71.2 | | | | C
Marya 1988^37^ India [3243609] | Pregnant women & infant 0–6 mo | Birth weight | 1° | Delivery | Vit D 1.2 mil IU total | 100 | g | NA | Final2990 | 2920, 3060 | Diff +190 | 90, 290^C^ | <0.001 | C
Marya 1988^37^ India [3243609] | Pregnant women & infant 0–6 mo | Birth weight | 1° | Delivery | No supplement | 100 | | NA | 2800 | 2730, 2870 | | | | C
Marya 1988^37^ India [3243609] | Pregnant women & infant 0–6 mo | Birth length | 2° | | Vit D 1.2 mil IU total | 100 | cm | NA | Final 50.06 | 49.7, 50.4 | Diff +1.6 | 1.1, 2.1^C^ | <0.001 | C
Marya 1988^37^ India [3243609] | Pregnant women & infant 0–6 mo | Birth length | 2° | | No supplement | 100 | | NA | 48.45 | 48.1, 48.8 | | | | C
Marya 1981^41^ [7239350]^E^ | Pregnant women & infant 0–6 mo | Birth weight | 2° | Delivery | Vit D 1.2 mil IU total | 20 | g | NA | Final 3140 | 2940, 3340 | Diff +410 | 166, 654^C^ | 0.001 | C
Marya 1981^41^ [7239350]^E^ | Pregnant women & infant 0–6 mo | Birth weight | 2° | Delivery | Vit D 1200 IU+ 375 mg Ca (3^rd^ trimester) | 25 | g | NA | Final 2890 | 2760, 3020 | Diff +160 | 0, 320^C^ | 0.05 | C
Marya 1981^41^ [7239350]^E^ | Pregnant women & infant 0–6 mo | Birth weight | 2° | Delivery | No supplement | 75 | | NA | 2730 | 2650, 2810 | | | | C
Mallet 1986^40^ France (48° N) [3755517] | Pregnant women & infant 0–6 mo | Birth weight | 2° | delivery | Vit D 1000 IU | 21^D^ | g | NA | Final 3370 (80) | | Diff +160 | | NS | C
Mallet 1986^40^ France (48° N) [3755517] | Pregnant women & infant 0–6 mo | Birth weight | 2° | delivery | Vit D 200,000 IU 1x dose | 27^D^ | | NA | 3210 (90) | | | | | C

A See Table 1 in original paper for complete results stratified by North vs. South China and birth in spring vs. fall

B See Table 3 in original paper for results on 1 mo and 4 mo

C Estimated from available data

D Estimated from number of mothers; number of infants not reported

E This is not an RCT; the supplemented groups were randomized, but not the control (non-supplemented group); data from comparisons between the supplemented groups not reported.

Table 7 Vitamin D and growth outcomes: Results of cohort studies

Author Year Study Name PMID | Life Stage | Outcome (n/N; Incidence) | Followup Duration | Maternal 25(OH)D concentration, nmol/L | No. in Category | Final value | Final SD | P value | Study Quality
Morley 2006^43^ Australia [16352684] | Pregnant women; infant 0–6 mo | Birth weight (N=374) | Delivery | <28 at 28–32 wk | 27 | 3397 g | 57 | NS | B
Morley 2006^43^ Australia [16352684] | Pregnant women; infant 0–6 mo | Birth weight (N=374) | Delivery | ≥28 at 28–32 wk | 347 | 3555 | 52 | NS | B
Morley 2006^43^ Australia [16352684] | Pregnant women; infant 0–6 mo | Birth length (N=374) | Delivery | <28 at 28–32 wk | 27 | 49.8 cm | 2.7 | NS | B
Morley 2006^43^ Australia [16352684] | Pregnant women; infant 0–6 mo | Birth length (N=374) | Delivery | ≥28 at 28–32 wk | 347 | 50.4 | 2.4 | NS | B
Gale 2008^42^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Birth weight (N=466) | Delivery | <30 (Quartile) | nd | 3.38 kg | 0.46 | 0.25^A^ | C
Gale 2008^42^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Birth weight (N=466) | Delivery | 30–50 | nd | 3.40 | 0.56 | 0.25^A^ | C
Gale 2008^42^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Birth weight (N=466) | Delivery | 50–75 | nd | 3.49 | 1.57 | 0.25^A^ | C
Gale 2008^42^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Birth weight (N=466) | Delivery | >75 | nd | 3.43 | 0.51 | 0.25^A^ | C
Gale 2008^42^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Weight at 9 mo (N=440) | 9 mo | <30 | nd | 15.9 | 1.14 | 0.58 | C
Gale 2008^42^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Weight at 9 mo (N=440) | 9 mo | 30–50 | nd | 15.8 | 1.26 | 0.58 | C
Gale 2008^42^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Weight at 9 mo (N=440) | 9 mo | 50–75 | nd | 16.1 | 1.34 | 0.58 | C
Gale 2008^42^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Weight at 9 mo (N=440) | 9 mo | >75 | nd | 15.9 | 1.09 | 0.58 | C
Gale 2008^42^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Weight at 9 y (N=178) | 9 y | <30 | nd | 27.4 kg | 1.19 | 0.10 | C
Gale 2008^42^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Weight at 9 y (N=178) | 9 y | 30–50 | nd | 29.4 | 1.21 | 0.10 | C
Gale 2008^42^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Weight at 9 y (N=178) | 9 y | 50–75 | nd | 30 | 1.20 | 0.10 | C
Gale 2008^42^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Weight at 9 y (N=178) | 9 y | >75 | nd | 29.3 | 1.19 | 0.10 | C
Gale 2008^42^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Birth length (N=466) | Delivery | <30 | nd | 50 cm | 1.83 | 0.15 | C
Gale 2008^42^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Birth length (N=466) | Delivery | 30–50 | nd | 50 | 2.29 | 0.15 | C
Gale 2008^42^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Birth length (N=466) | Delivery | 50–75 | nd | 50.5 | 2.25 | 0.15 | C
Gale 2008^42^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Birth length (N=466) | Delivery | >75 | nd | 50.1 | 2.09 | 0.15 | C
Gale 2008^42^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Length at 9 mo (N=440) | 9 mo | <30 | nd | 71.2 cm | 2.85 | 0.86 | C
Gale 2008^42^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Length at 9 mo (N=440) | 9 mo | 30–50 | nd | 71.4 | 2.60 | 0.86 | C
Gale 2008^42^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Length at 9 mo (N=440) | 9 mo | 50–75 | nd | 71.7 | 2.89 | 0.86 | C
Gale 2008^42^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Length at 9 mo (N=440) | 9 mo | >75 | nd | 71.1 | 2.67 | 0.86 | C
Gale 2008^42^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Height at 9 y (N=178) | 9 y | <30 | nd | 129.6 cm | 5.88 | 0.19 | C
Gale 2008^42^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Height at 9 y (N=178) | 9 y | 30–50 | nd | 131.5 | 6.66 | 0.19 | C
Gale 2008^42^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Height at 9 y (N=178) | 9 y | 50–75 | nd | 131.8 | 5.09 | 0.19 | C
Gale 2008^42^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Height at 9 y (N=178) | 9 y | >75 | nd | 130.6 | 6.45 | 0.19 | C

A Non-adjusted

Six RCTs34–40 and one nonrandomized comparative study41 in eight publications reported on the effect of vitamin D supplementation on growth parameters in infants and children. Two cohort studies reported on the association between maternal serum 25(OH)D concentration and her offspring’s growth parameters.42,43 The number of subjects in the RCTs ranged from 19 to 200. The two cohort studies had 374 and 466 subjects, respectively. The latitudes of the studies ranged from 38° to 51°. Four studies administered vitamin D exclusively to expectant mothers during the third trimester of pregnancy. One study administered vitamin D to both the lactating mothers and her offspring. Two studies administered vitamin D only to the infants or children. Followup ranged from delivery until 9 years. Methodological quality of two studies were rated B and seven studies were rated C. The studies were limited by such factors as incomplete reporting and small sample sizes.

Infant 0 – 6 months; 7 months - 2 years; pregnant or lactating women

One RCT from UK administered vitamin D 1000 IU/d or placebo to 126 expectant mothers (first generation Asian immigrants) during the third trimester and found no significant difference between the infants’ birth weights or birth lengths and those of the control population.34,38 There were twice as many low birth weight infants (<2500 g) in the control group compared to the supplemented group (21.7 percent vs. 11.9 percent); however, this difference was not significant. A study from US supplemented 10 lactating mothers with vitamin D 400 IU/d and their infants with 300 IU/d for 6 months. Compared to the group where nine mothers received 6400 IU/d and their infants none, there was no significant difference in the infants’ weight or length at 1 month, 4 months, and 7 months of age.39 A study from China randomly assigned 255 newborn infants to 100, 200, or 400 IU/d of vitamin D for 6 months and reported no significant difference in weight or length among the three groups at 6 months of age.36 One study from India randomly selected 100 expectant mothers to receive a total of 1.2 million IU of vitamin D (600,000 IU of vitamin D_2_ in 7^th^ and 8^th^ month) during the third trimester. The newborns’ birth weight was significantly increased compared to those from 100 unsupplemented expectant mothers (difference 190 g).37 Important elements of the study methodology like randomization technique and any blinding of outcome assessors were not reported. An earlier nonrandomized comparison from the same study center involving smaller samples reported similar findings.41 The estimated baseline mean dietary vitamin D intake in the expectant mothers from these two studies was less than 30 to 35 IU/d (the validity of these measures is unclear). An RCT from France supplemented 48 expectant mothers with either vitamin D 1000 IU/d in the third trimester or 200,000 IU one time dose at 7 month pregnancy and found no significant difference in the infants’ birth weights between the two methods.40 A cohort study from Australia analyzed the maternal serum 25(OH)D concentration in 374 women at 28–32 week gestation (geometric mean in winter 48 nmol/L; summer 69 nmol/L) and found no association with infant birth weight or length.43 One cohort study from UK analyzed the serum 25(OH)D concentration in 466 white women in late pregnancy (~33 wk) and found the concentrations (from <30 to >75 nmol/L) were not related to their offspring’s weight or height at birth, 9 months, and 9 years.42

9 – 18 years

One RCT of vitamin D_3_ (placebo, 200, or 2000 IU/d for 1 year) on girls in Lebanon aged 10–17 years found no significant difference at 1 year followup in weight or height among the 34 girls who were premenarchal at time of enrollment.35

Findings by life stage

- 0 – 6 mo One RCT found that supplementing expectant mothers with vitamin D 1000 IU/d during the 3^rd^ trimester has no effect on infant birth weight or length. Another RCT found that supplementing expectant mothers with a total of 1.2 million IU of vitamin D during the 3^rd^ trimester effected a significant increase in birth weight (+190 g). Background diet is low in vitamin D in this study. A study compared supplementing lactating mothers with vitamin D 400 IU/d and their infants 300 IU/d for 6 months with mothers supplemented with 6400 IU/d and their infants none, there was no significant difference in the infants’ weight or length at 1 month, 4 months, and 7 months of age. Another study compared supplementing newborn infants with 100, 200, or 400 IU/d of vitamin D for 6 months and reported no significant difference in weight or length at 6 months of age. An RCT supplemented expectant mothers with either vitamin D 1000 IU/d during the third trimester or 200,000 IU one time dose at 7 month pregnancy and found no significant difference in the infants’ birth weights between the two methods. A cohort study analyzed the maternal serum 25(OH)D concentration at 28–32 week gestation (geometric mean in winter 48 nmol/L; summer 69 nmol/L) and found no association with infant birth weight or length. Another cohort study found that serum 25(OH)D concentration (ranged from <30 to >75 nmol/L) in late pregnancy (~33 wk) was not related to the newborn’s weight or height at birth, 9 months, and 9 years.
- 7 mo – 2 y A cohort study found that serum 25(OH)D concentration (ranged from <30 to >75 nmol/L) in late pregnancy (~33 wk) was not related to the newborn’s weight or height at birth, 9 months, and 9 years.
- 3 – 8 y No study covered this life stage.
- 9 – 18 y A cohort study found that serum 25(OH)D concentration (ranged from <30 to >75 nmol/L) in late pregnancy (~33 wk) was not related to the newborn’s weight or height at birth, 9 months, and 9 years. One RCT of vitamin D_3_ (placebo, 200, or 2000 IU/d for 1 year) on girls 10–17 years old found no significant difference at 1 year followup in weight or height among the girls who were premenarchal at time of enrollment.
- 19 – 50 y Not reviewed
- 51 – 70 y Not reviewed
- ≥71 y Not reviewed
- Postmenopause Not reviewed
- Pregnant & lactating women One RCT found that supplementing expectant mothers with vitamin D 1000 IU/d during the 3^rd^ trimester has no effect on infant birth weight or length. Another RCT found that supplementing expectant mothers with a total of 1.2 million IU of vitamin D during the 3^rd^ trimester effected a significant increase in birth weight (+190 g). Background diet is low in vitamin D in this study. A study compared supplementing lactating mothers with vitamin D 400 IU/d and their infants 300 IU/d for 6 months with mothers supplemented with 6400 IU/d and their infants none, there was no significant difference in the infants’ weight or length at 1 month, 4 months, and 7 months of age. An RCT supplemented expectant mothers with either vitamin D 1000 IU/d during the third trimester or 200,000 IU one time dose at 7 month pregnancy and found no significant difference in the infants’ birth weights between the two methods.

### Vitamin D and Cardiovascular Disease

Synopsis

No qualified systematic reviews have evaluated the association between vitamin D intake or serum 25(OH)D concentrations and incidence of hypertension. One RCT of almost 2700 elderly British who received either vitamin D3 100,000 IU every 4 months or placebo for 5 years found no statistically significant difference in event rates for various cardiovascular outcomes, including total events and cardiovascular deaths. No effects were also found in subgroup analyses of men and women. Three cohort and one nested case-control studies have analyzed the association between serum 25(OH)D concentrations and cardiovascular outcomes (cardiovascular events, nonfatal myocardial infarction or fatal coronary heart disease, cardiovascular death, myocardial infarction, and stroke). Significant associations were found between progressively lower 25(OH)D concentration and progressively increased risk of cardiovascular events in two studies of people approximately 40 to 75 years old. No significant associations were found between serum 25(OH)D concentrations and cardiovascular death, myocardial infarction, or stroke in one study each.

Detailed presentation

(Tables 8, 9, 10 & 11; Figure 6)

Table 8 Vitamin D and cardiovascular outcomes: Characteristics of RCTs

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Trivedi 200^44^ Ipswich, UK (52°N) [12609940] | - Health status; - Mean age (range), y; - Male (%) | General population 75 (65–85) 76% | 742 mg/day (at 4 years, no difference by treatment allocation) | Vit D_3_ 100,000 IU vs placebo every 4 months | 76% with at least 80% compliance; 66% at last dose (80% if excluding deaths)

Table 9 Vitamin D and cardiovascular outcomes: Results of RCTs

Author Year Study Name [PMID] | Age Range, Sex (Subgp) | Outcome | 1°/2° | Mean Followup | Interventions, Daily Dose | n Event | N Total | Outcome Metric (Comparison) | Result | 95% CI | P Btw | Study Quality
Trivedi 200^44^ [12609940] | 65–85 y, Both | CVD, total | 2° | 5 y | Vit D_3_ 100,000 IU every 4 mo | 477 | 1345 | Age adj RR (Vit D/Placebo) | 0.90^A^ | 0.77, 1.06 | 0.22 | B
Trivedi 200^44^ [12609940] | 65–85 y, Both | CVD, total | 2° | 5 y | Placebo | 503 | 1341 | | | | | B
Trivedi 200^44^ [12609940] | 65–85 y, Both | IHD, total | 2° | 5 y | Vit D_3_ | 224 | 1345 | Age adj RR (Vit D/Placebo) | 0.94^A^ | 0.77, 1.15 | 0.57 | B
Trivedi 200^44^ [12609940] | 65–85 y, Both | IHD, total | 2° | 5 y | Placebo | 233 | 1341 | | | | | B
Trivedi 200^44^ [12609940] | 65–85 y, Both | CeVD, total | 2° | 5 y | Vit D_3_ | 105 | 1345 | Age adj RR (Vit D/Placebo) | 1.02^A^ | 0.77, 1.36 | 0.87 | B
Trivedi 200^44^ [12609940] | 65–85 y, Both | CeVD, total | 2° | 5 y | Placebo | 101 | 1341 | | | | | B
Trivedi 200^44^ [12609940] | 65–85 y, Both | CVD death | 1° | 5 y | Vit D_3_ | 101 | 1345 | Age adj RR (Vit D/Placebo) | 0.84^A^ | 0.65, 1.10 | 0.20 | B
Trivedi 200^44^ [12609940] | 65–85 y, Both | CVD death | 1° | 5 y | Placebo | 117 | 1341 | | | | | B
Trivedi 200^44^ [12609940] | 65–85 y, Both | IHD death | 1° | 5 y | Vit D_3_ | 42 | 1345 | Age adj RR (Vit D/Placebo) | 0.84^A^ | 0.56, 1.27 | 0.41 | B
Trivedi 200^44^ [12609940] | 65–85 y, Both | IHD death | 1° | 5 y | Placebo | 49 | 1341 | | | | | B
Trivedi 200^44^ [12609940] | 65–85 y, Both | CeVD death | 1° | 5 y | Vit D_3_ | 28 | 1345 | Age adj RR (Vit D/Placebo) | 1.04^A^ | 0.61, 1.20 | 0.89 | B
Trivedi 200^44^ [12609940] | 65–85 y, Both | CeVD death | 1° | 5 y | Placebo | 26 | 1341 | | | | | B

A Similar results for subgroups of men and women

Table 10 Vitamin D and cardiovascular outcomes: Characteristics of cohort studies

Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Specific CVD Outcomes
Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV exposure | Lifestyle | Specific CVD Outcomes
Wang 2008^45^ Framingham Offspring Framingham, MA (mostly) (42°N) [18180395] | - Health status; - Mean age(SD), y; - Male (%) | No CVD 59 (9) 45 | Assay methodSeason blood drawn | RIA (DiaSorin) All | Outcome stratified by 2 or 3 categories | XA | X | X | X | X^A^ | X | CVD event
Giovannucci2008^46^ HPFS US (various) [18541825] | - Health status; - Mean age (range), y; - Male (%) | No CVD 64 (40–75) 100 | Dietary assessment methodInternal validation? (y/n) | RIA (Hollis 1993) All | Outcome stratified by 4 categories^B^ | X | X | X | X | X | X | Nonfatal MI or fatal CHD
Melamed 2008^47^ NHANES III US (various) [18695076] | - Health status; - Mean age (range), y; - Male (%) | Any 45 (≥20) 46 | Assay methodSeason blood drawn | RIA (DiaSorin) All (even distribution) | Outcome stratified by 4 categories | X | X | X | X | X | X | CVD death
Marniemi 2005^48^ Turku, Finland (60°N) [15955467] | - Health status; - Mean age (range), y; - Male (%) | Any 79 (65–99) 48 | Assay methodSeason blood drawn | RIA (Incstar) All | Outcome stratified by tertiles | | X | | | | X | MI Stroke

A Not in 3-category analysis

B Case-control study

Table 11 Vitamin D and cardiovascular outcomes: Results of cohort studies

Author Year Study Name [PMID] | Age Range, Sex | Outcome (n/N; Incidence) | Followup Duration (Time to Dx) | Vit D Measure | Concentration, nmol/L | No. of Cases | No. in Category | Adjusted OR | 95% CI | P for Trend | Study Quality
CVD Events
Both Sexes
Wang 2008^45^ Framingham Offspring [18180395] | Mean (SD) 59 (9), Both | CVD event (120/1739; 0.069) | 5.4 y | 25(OH)D | <37.5 | 50 | 481 | 1.70 | 1.08, 2.67^*^ | 0.02^A^ | A
Wang 2008^45^ Framingham Offspring [18180395] | Mean (SD) 59 (9), Both | CVD event (120/1739; 0.069) | 5.4 y | 25(OH)D | ≥37.5 | 70 | 1258 | 1 | Reference | 0.02^A^ | A
Wang 2008^45^ Framingham Offspring [18180395] | Mean (SD) 59 (9), Both | CVD event (120/1739; 0.069) | 5.4 y | 25(OH)D | <25 | nd | nd | 1.80 | 1.05, 3.08^*^ | 0.01 | C
Wang 2008^45^ Framingham Offspring [18180395] | Mean (SD) 59 (9), Both | CVD event (120/1739; 0.069) | 5.4 y | 25(OH)D | 25–37.5 | nd | nd | 1.53 | 1.00, 2.36* | 0.01 | C
Wang 2008^45^ Framingham Offspring [18180395] | Mean (SD) 59 (9), Both | CVD event (120/1739; 0.069) | 5.4 y | 25(OH)D | ≥37.5 | 70 | 1258 | 1 | Reference | 0.01 | C
Men
Giovannucci 2008^46^ HPFS [18541825] | 40–75 y, Men | Nonfatal MI or fatal CHD (454 cases; 1354 controls) | 10 y | 25(OH)D | ≤37.5 | 63 | 150 | 2.09 | 1.24, 3.54 | 0.02^B,C^ | A
Giovannucci 2008^46^ HPFS [18541825] | 40–75 y, Men | Nonfatal MI or fatal CHD (454 cases; 1354 controls) | 10 y | 25(OH)D | 37.5–56.25 | 156 | 463 | 1.43 | 0.96, 2.13 | 0.02^B,C^ | A
Giovannucci 2008^46^ HPFS [18541825] | 40–75 y, Men | Nonfatal MI or fatal CHD (454 cases; 1354 controls) | 10 y | 25(OH)D | 56.25–75 | 165 | 464 | 1.60 | 1.10, 2.32 | 0.02^B,C^ | A
Giovannucci 2008^46^ HPFS [18541825] | 40–75 y, Men | Nonfatal MI or fatal CHD (454 cases; 1354 controls) | 10 y | 25(OH)D | >75 | 70 | 277 | 1 | Reference | 0.02^B,C^ | A
CVD Death
Both Sexes
Melamed 2008^47^ NHANES III [18695076] | ≥20 y, Both | CVD death (777/13,331; 0.058) | 8.7 y | 25(OH)D | <44.5 | nd | nd | 1.20 | 0.87, 1.64 | nd | C
Melamed 2008^47^ NHANES III [18695076] | ≥20 y, Both | CVD death (777/13,331; 0.058) | 8.7 y | 25(OH)D | 44.5–60.75 | nd | nd | 0.88 | 0.69, 1.14 | nd | C
Melamed 2008^47^ NHANES III [18695076] | ≥20 y, Both | CVD death (777/13,331; 0.058) | 8.7 y | 25(OH)D | 60.75–80.25 | nd | nd | 0.83 | 0.65, 1.07 | nd | C
Melamed 2008^47^ NHANES III [18695076] | ≥20 y, Both | CVD death (777/13,331; 0.058) | 8.7 y | 25(OH)D | >80.25 | nd | nd | 1 | Reference | nd | C
Myocardial Infarction
Both Sexes
Marniemi 2005^48^ [15955467] | 65–99 y, Both | MI (130/755; 0.172) | 10 y | 25(OH)D | nd | nd | ~252 | 1 | Reference | nd | C
Marniemi 2005^48^ [15955467] | 65–99 y, Both | MI (130/755; 0.172) | 10 y | 25(OH)D | nd | nd | ~252 | 0.99 | 0.64, 1.53 | nd | C
Marniemi 2005^48^ [15955467] | 65–99 y, Both | MI (130/755; 0.172) | 10 y | 25(OH)D | nd | nd | ~252 | 0.77 | 0.47, 1.27 | nd | C
Marniemi 2005^48^ [15955467] | 65–99 y, Both | MI (130/755; 0.172) | 10 y | 1,25(OH)_2_D | nd | nd | ~252 | 1 | Reference | nd | C
Marniemi 2005^48^ [15955467] | 65–99 y, Both | MI (130/755; 0.172) | 10 y | 1,25(OH)_2_D | nd | nd | ~252 | 1.05 | 0.68, 1.62 | nd | C
Marniemi 2005^48^ [15955467] | 65–99 y, Both | MI (130/755; 0.172) | 10 y | 1,25(OH)_2_D | nd | nd | ~252 | 0.82 | 0.52, 1.30 | nd | C
Stroke
Both Sexes
Marniemi 2005^48^ [15955467] | 65–99 y, Both | Stroke (70/755; 0.093) | 10 y | 25(OH)D | nd | nd | ~252 | 1 | Reference | nd | C
Marniemi 2005^48^ [15955467] | 65–99 y, Both | Stroke (70/755; 0.093) | 10 y | 25(OH)D | nd | nd | ~252 | 1.13 | 0.62, 2.05 | nd | C
Marniemi 2005^48^ [15955467] | 65–99 y, Both | Stroke (70/755; 0.093) | 10 y | 25(OH)D | nd | nd | ~252 | 1.00 | 0.51, 1.94 | nd | C
Marniemi 2005^48^ [15955467] | 65–99 y, Both | Stroke (70/755; 0.093) | 10 y | 1,25(OH)_2_D | nd | nd | ~252 | 1 | Reference | nd | C
Marniemi 2005^48^ [15955467] | 65–99 y, Both | Stroke (70/755; 0.093) | 10 y | 1,25(OH)_2_D | nd | nd | ~252 | 0.63 | 0.37, 1.09 | nd | C
Marniemi 2005^48^ [15955467] | 65–99 y, Both | Stroke (70/755; 0.093) | 10 y | 1,25(OH)_2_D | nd | nd | ~252 | 0.41 | 0.22, 0.77^*^ | nd | C

* Statistically significant (P<0.05)

A Multivariable Cox regression with continuous 25(OH)D and regression splines with nonlinear relationships suggests an increased hazard of CVD events at serum 25(OH)D concentrations below approximately 50–55 nmol/L. See Figure 2 on page 508 of article.

B Adjusted regression analyses found OR=0.98 (0.96, 0.998) per 2.5 nmol/L increase in 25(OH)D and risk reduction of −2.1% (−0.2%, −4.0%) per 2.5 nmol/L increase in serum 25(OH)D concentration.

C In a subgroup analysis of participants on no cholesterol lowering drugs at baseline, comparing the highest serum 25(OH)D concentration category (>75 nmol/L) to the lowest (≤37.5 nmol/L), adjusted RR=2.30 (1.33, 3.97).

Figure 6 Cardiovascular outcomes risk stratified by vitamin D concentration

Total cardiovascular events

Total cardiovascular events were evaluated by an RCT,44 the Framingham Offspring Study (FOS),45 and a nested case-control study derived from the Health Professionals Follow-up Study (HPFS).46 The RCT found no significant effect of vitamin D; both cohort studies found significant associations between lower serum 25(OH)D concentrations and increased rates of outcomes.

The RCT randomized almost 2700 elderly participants (65–85 years) from the general population in Ipswich, UK (52° N) to vitamin D_3_ 100,000 IU every 4 months or placebo.44 After 5 years, 36 percent of the participants had a cardiac or cerebrovascular event, but there was no statistically significant difference between those taking vitamin D or placebo. Similar results were found in subgroups of men and women. The RCT was rated quality B primarily due to inadequate verification of outcomes.

The FOS cohort evaluated 1739 men and women with no history of cardiovascular disease and a mean age of 59 years (based on the standard deviation, with an approximate rage of 41 to 77 years).45 After 5.4 years, 6.9 percent had a cardiovascular event (including myocardial infarction, coronary insufficiency, angina, stroke, transient ischemic attack, claudication, and heart failure). Overall, the methodological quality of the study was A; though their secondary analysis of three categories of serum 25(OH)D concentrations (as opposed to two categories) was rated C due to incomplete reporting and lack of adjustment for important variables including season of blood draw. In their primary analysis, people with serum 25(OH)D concentrations less than 37.5 nmol/L were 70 percent more likely (P=0.02) to have a cardiovascular event. In their secondary analysis, those with 25(OH)D concentrations between 25 and 37.5 nmol/L were about 50 percent more likely (P=0.01) to have an event than those with higher concentrations. Furthermore, a multivariable analysis of continuous 25(OH)D concentrations suggested increased likelihoods of cardiovascular events in those with 25(OH)D concentrations below approximately 50 to 55 nmol/L.

In a nested case-control study of the HPFS, 454 men 40 to 75 years old with no cardiovascular history who had a nonfatal myocardial infarction or coronary heart disease death over a 10 year period were matched with 1354 controls.46 The methodological quality of the analysis was A, although due to limitations on analyzable serum, the investigators had to use a case-control analysis instead of a complete analysis of all eligible men in the HPFS. Across four categories of men based on their serum 25(OH)D concentrations, lower concentrations were significantly associated with increased cardiovascular events (trend across categories P=0.02). Compared with men who had 25(OH)D concentrations above 75 nmol/L, those with 25(OH)D concentrations 56 to 75 nmol/L had an adjusted relative risk (RR) of 1.6 (95 percent CI 1.1, 2.3), those with 25(OH)D 37.5 to 56 nmol/L had an RR of 1.4 (95 percent CI 0.96, 2.1), and those with 25(OH)D below 37.5 nmol/L had an RR of 2.1 (95 percent CI 1.2, 3.5).

Cardiovascular death

The British RCT of vitamin D_3_100,000 IU every 4 months versus placebo analyzed cardiovascular death as a primary outcome; 8 percent of the participants had cardiovascular deaths within 5 years.44 Fewer people taking vitamin D_3_ supplements had cardiovascular deaths (RR = 0.84), but this finding was not statistically significant (95 percent CI 0.65, 1.10). Similar results were found in subgroups of men and women.

An analysis of NHANES III (methodological quality C) evaluated cardiovascular death (due to hypertensive disease, ischemic heart disease, arrhythmia, heart failure, cerebrovascular disease, atherosclerosis or other disease of the arteries) in over 13,000 men and women regardless of baseline medical history.47 During almost 9 years of followup, 5.8 percent had a cardiovascular death. The analysis compared four categories of serum 25(OH)D concentrations ranging from less than 44.5 nmol/L to more than 80 nmol/L. No significant association was found between serum 25(OH)D concentration and cardiovascular death.

Ischemic heart disease

The RCT evaluated total ischemic heart disease.44 In this elderly British population, 17 percent had an ischemic heart disease event; no effect of vitamin D_3_ supplementation was found. Similar results were found in subgroups of men and women.

Ischemic heart disease death

The RCT evaluated total ischemic heart disease death as a primary outcome.44 In the trial, 3.4 percent had an ischemic heart disease event; no effect of vitamin D_3_ supplementation was found (RR = 0.84 [95 percent CI 0.56, 1.27]). Similar results were found in subgroups of men and women.

Myocardial infarction

In one small analysis, 755 elderly (age 65 to 99 years) Finnish men and women, regardless of cardiovascular history, were evaluated on the basis of myocardial infarction (methodological quality C due to lack of reporting of relevant data including information on the serum 25(OH)D or 1,25(OH)_2_D concentrations within the tertiles).48

During 10 years of followup, 17 percent of the participants had a myocardial infarction. Both analyses of serum 25(OH)D and 1,25(OH)_2_D concentrations found no significant association with risk of myocardial infarction.

Stroke

The RCT evaluated total cerebrovascular disease.44 In this elderly British population, 7.7 percent had a cerebrovascular event; no effect of vitamin D3 supplementation was found. Similar results were found in subgroups of men and women.

Stroke was evaluated in the same small Finnish study. During 10 years of followup, 9.3 percent of the participants had a stroke. Both analyses of serum 25(OH)D and 1,25(OH)_2_D concentrations found no significant association with risk of stroke.

Cerebrovascular death

The RCT evaluated cerebrovascular disease death as a primary outcome.44 In the trial, 2.0 percent had a fatal stroke; no effect of vitamin D_3_ supplementation was found. Similar results were found in subgroups of men and women.

Findings per vitamin D concentration

The RCT compared vitamin D3 supplementation 100,000 IU every 4 months with placebo, but found no effect on cardiovascular outcomes. Two cohort studies found a significant association between higher serum 25(OH)D concentrations and lower risk of combined cardiovascular events. Both found that those people in the highest 25(OH)D category analyzed within each study had the lowest risk. The FOS used a maximum threshold of 37.5 nmol/L; the HPFS used a maximum threshold of 75 nmol/L. The FOS provided a graphic representation of a multivariable regression of continuous 25(OH)D concentrations (Figure 2 in the study).45 The risk of cardiovascular events rose below 37 to 50 nmol/L serum 25(OH)D concentration. The Finnish cohort did not report the range of serum 25(OH)D and 1,25(OH)_2_D concentrations.48

Findings per age and sex

The single RCT included elderly people from the general population. No effects on various cardiovascular events were found. Subgroup analyses of men and women yielded similar findings. The four cohort studies included adults across the full age range. Three of the cohorts included about half men and women; one included only men. None evaluated potential differences in associations based on age or sex, but no differences were evident across studies.

Findings by life stage

- 0–6 mo Not reviewed
- 7 mo – 2 y Not reviewed
- 3–8 y Not reviewed
- 9–18 y Not reviewed
- 19–50 y For cardiovascular events, only a minority of evaluated participants were within this life stage (almost all above 40 years). The NHANES III study, which found no association between serum 25(OH)D concentration and cardiovascular death, included largely people within this life stage.
- 51–70 y The majority of people investigated for the association between serum 25(OH)D concentration and cardiovascular events were within this life stage. Significant associations were found between lower serum 25(OH)D concentrations and increased rates of cardiovascular events, across a range of 25(OH)D concentrations. The NHANES III study likely included many people within this life stage; no association was found with cardiovascular death.
- ≥71 y The majority of participants in the British RCT included men and women within this age group. Vitamin D supplementation was not found to have an effect on
- Postmenopause Only the RCT provided data on a subgroup that included only postmenopausal women. No effect of vitamin D_3_ supplementation was found.
- Pregnant & lactating women Not reviewed

### Vitamin D and Body Weight

We searched for systematic reviews and primary studies that evaluated associations between vitamin D intake or body stores and incidence of overweight or obesity; no such studies were found. For the outcome weight change (in kilograms or body mass index units), we included only randomized controlled trials. The EPC and the TEP agreed that the limited resources would not be expended on reviewing observational studies for the surrogate outcome body weight (where overweight or obesity are considered to be the clinical outcomes). We included only studies of adults. Studies of weight gain in children are included in the “Growth” section.

Synopsis

No qualified systematic reviews have evaluated the association between vitamin D intake or serum 25(OH)D concentrations and body weight in adults. Three RCTs from Finland, Norway, and India compared different doses of vitamin D (300 IU daily, 20,000 or 40,000 IU weekly, or 120,000 IU every 2 weeks) to placebo, with or without supplemental calcium in both groups. The study participants also varied: they were postmenopausal women, obese men and women, or only obese men. In the Finnish and Norwegian studies, the participants on average, gained weight in all groups over 1 or 3 years; in the Indian study weight remained mostly stable over 6 weeks. All studies found no difference in weight change with or without vitamin D supplementation.

Detailed presentation

(Tables 12 & 13)

Table 12 Vitamin D and weight: Characteristics of RCTs

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Heikkinen 1997^49^ Kuopio ORFPS Kuopio, Finland (63°N) [9405029] | - Health status; - Mean age (range), y; - Male (%) | All, post-menopause 53 (47–56) 0 | nd | Vit D_3_ & Ca lactate vs Placebo & Ca lactate | nd
Sneve 2008^50^ Tromsø, Norway (70°N) [19056900] | - Health status; - Mean age (range), y; - Male (%) | Healthy overweight and obese 48 (21–70) 36 | 25(OH)D 53.1±16.9 nmol/L Ca intake 940±398 mg/d | Vit D_3_ 40,000 IU per week vs Vit D_3_ 20,000 IU per week vs Placebo All: Ca carbonate 500 mg/d | The compliance rate for cholecalciferol/placebo capsules were 95% in all 3 groups, and for the calcium tablets 81–85% across all 3 groups.
Nagpal 2009^51^ New Delhi, India (28.5°N) [19125756] | - Health status; - Mean age (SD), y; - Male (%) | Healthy, obese 44 (8) 100% | 25(OH)D: 36.5 nmol/L (treatment group), 30.0 nmol/L (control group) | Vit D_3_ 120,000 IU every 2 weeks vs Placebo | 100% (implied); supervised home visits | Excluded subjects who refused subsequent blood draws

Table 13 Vitamin D and weight: Results of RCTs

Author Year Study Name [PMID] | Age Range, Sex (Subgp) | Outcome | 1°/2° | Mean Followup | Interventions, Daily Dose | No. Analyzed | Unit | Baseline | Change | Change 95% CI | Net Diff | Net Diff 95% CI | P Btw | Study Quality
Isocaloric Diet
Heikkinen 1997^49^ Kuopio ORFPS [9405029] | 47–56 y, Women | Weight | 2° | 3 y | Vit D_3_ 300 IU + Ca lactate 93 mg | 83 | kg | 71.5 | +1.84% | +0.43%, +3.25% | −1.5% | −3.6%, +0.6%^A^ | NS^B^ | C
Heikkinen 1997^49^ Kuopio ORFPS [9405029] | 47–56 y, Women | Weight | 2° | 3 y | Ca lactate 93 mg | 95 | | 67.6 | +3.32% | +1.73%, 4.91% | | | | C
Sneve 2008^50^ [19056900] | 21–70 y, Both | Weight | 1° | 1 y | Vit D_3_ 40,000 IU weekly+ Ca carbonate 500 mg | 116 | kg | 101.0 | +0.1 | −0.6, +0.8 | −0.4 | −1.3, +0.5^A^ | NS | B
Sneve 2008^50^ [19056900] | 21–70 y, Both | Weight | 1° | 1 y | Vit D_3_ 20,000 IU weekly + Ca carbonate 500 mg | 106 | | 98.6 | +0.3 | −0.3, +0.9 | −0.2 | −1.1, +0.7^A^ | NS | B
Sneve 2008^50^ [19056900] | 21–70 y, Both | Weight | 1° | 1 y | Ca carbonate 500 mg | 112 | | 100.6 | +0.5 | −0.2, +1.2 | | | | B
Sneve 2008^50^ [19056900] | 21–70 y, Both | BMI | 1° | 1 y | Vit D_3_ 40,000 IU weekly + Ca carbonate 500 mg | 116 | BMI | 35.0 | 0.0 | −0.2, +0.2 | −0.2 | −0.6, +0.2^A^ | NS | B
Sneve 2008^50^ [19056900] | 21–70 y, Both | BMI | 1° | 1 y | Vit D3 20,000 IU weekly + Ca carbonate 500 mg | 106 | | 34.4 | +0.1 | −0.1, +0.3 | −0.1 | −0.4, +0.2^A^ | NS | B
Sneve 2008^50^ [19056900] | 21–70 y, Both | BMI | 1° | 1 y | Ca carbonate 500 mg | 112 | | 35.1 | +0.2 | −0.1, +0.5 | | | | B
Nagpal 2009^51^ New Delhi, India [19125756] | 44 (8, SD) Men | Weight | 2° | 6 wk | Vit D_3_ 120,000 IU every 2 wk | 35 | kg | nd | +0.03 | −0.6, +0.6 | +0.42 | −0.4, +1.2 | NS | C
Nagpal 2009^51^ New Delhi, India [19125756] | 44 (8, SD) Men | Weight | 2° | 6 wk | Placebo | 36 | | nd | −0.38 | −0.9, +0.2 | | | | C
Nagpal 2009^51^ New Delhi, India [19125756] | 44 (8, SD) Men | BMI | 2° | 6 wk | Vit D_3_ 120,000 IU every 2 wk | 35 | BMI | 26.7 | −0.02 | −0.2, +0.2 | +0.02 | −0.3, +0.3 | NS | B
Nagpal 2009^51^ New Delhi, India [19125756] | 44 (8, SD) Men | BMI | 2° | 6 wk | Placebo | 36 | | 26.0 | −0.04 | −0.3, +0.2 | | | | B

A Estimated from reported data

B Per estimated 95% confidence interval, P=0.17

Three RCTs of vitamin D reported body weight (or body mass index [BMI]) as an outcome. The Kuopio (Finland) Osteoporosis Risk Factor and Prevention Study (Kuopio ORFPS) included postmenopausal women in a four-arm study.49 Two of the study arms included hormone replacement treatment and are not further discussed here. The remaining two arms compared vitamin D_3_ 300 IU (83 women) versus placebo (95 women), where all women were taking low dose calcium lactate 500 mg/d (equivalent to 93 mg Ca^++^/d). Women on cholesterol-lowering medication at any point during the trial were excluded. The primary outcome of the trial was the serum lipid profile. The women ranged in age from 47 to 56 years. After 3 years, women, on average, gained weight in both study arms (about 1–2 kg). Those in the placebo arm gained an absolute 1.5 percent more weight than those in the vitamin D arm, but the difference was not statistically significant. The study had a methodological quality of C due to an uneven distribution of body weights between study arms at baseline (means 71.5 and 67.6 kg) and an overall withdrawal rate of over 30 percent.

The second trial was conducted in Norway among healthy overweight and obese women and men.50 The participants’ mean baseline serum 25(OH)D concentration was 53 nmol/L. The trial compared vitamin D_2_ 40,000 IU weekly (116 participants completed), 20,000 IU weekly (106 participants), and placebo (112 participants). All study participants also took calcium carbonate 500 mg daily. Almost all participants complied with the vitamin D (or placebo). Changes in weight and BMI were primary outcomes. The participants ranged in age from 21 to 70 years. After 1 year, changes in weight were small (increases of 0.1–0.5 kg) in each trial group. Compared to the placebo group, those taking the larger dose of vitamin D had less weight gain than those taking the smaller dose, but none of the differences among study groups were statistically significant. The study was rated methodological quality B, primarily due to the high dropout rate (25 percent), which was not explained.

The third trial was conducted in New Delhi, India among healthy obese men.51 The participants’ mean baseline serum 25(OH)D concentration was about 33 nmol/L. The trial compared vitamin D_3_ 120,000 given under supervised conditions every 2 weeks and placebo in 100 men, of whom 71 were analyzed; most dropouts occurred because of refusals for subsequent blood draws (to assess the primary outcome). After 6 weeks, weight in kg and BMI were essentially stable, with no difference in weight change between the interventions. The study was rated methodological quality B because of the high dropout rate; for weight (in kg), the study was of quality C because baseline weights were not reported.

Findings per vitamin D dose

There was a lack of effect found across a range of doses from 300 IU to 8570 IU (prorated) daily.

Findings per age and sex

There was a lack of effect found in studies both of men mostly in their 40s, somewhat older people of both sexes, and postmenopausal women.

Findings by life stage

- 0–6 mo Not reviewed
- 7 mo–2 y Not reviewed
- 3–8 y Not reviewed
- 9–18 y Not reviewed
- 19–50 y No effect was found in one trial of men mostly within this life stage after 6 weeks.
- 51–70 y The majority of people in the trials were within this life stage. No significant effect was found on weight from vitamin D supplementation for 1 or 3 years.
- ≥71 y No data
- Postmenopause All the women in the Finnish trial were postmenopausal.
- Pregnant & lactating women Not reviewed

### Vitamin D and Cancer

#### Cancer from all causes and total cancer mortality

Synopsis

No qualified systematic reviews have evaluated relationships between vitamin D and total cancer incidence or mortality. One RCT showed no effect of combined vitamin D_3_ (1000 IU/d) and calcium (~1500 mg/d) supplementation versus calcium supplementation (~1500 mg/d) alone on the risk of total cancer in healthy postmenopausal women (>55 years old) living in Nebraska (latitude 41°N). Another RCT also found no difference in total cancer mortality or incidence between supplemental vitamin D_3_ (100,000 IU every 4 months) and placebo in elderly (71+ years old) men and women living in the United Kingdom (latitude 52° N). Both RCTs were rated B quality.

Analyses using NHANES III data (general adult populations living in the US) showed no significant association between baseline 25(OH)D concentrations and total cancer mortality.

Detailed presentation

(Tables 14, 15, 16 & 17)

Table 14 Vitamin D and total cancer: Characteristics of RCTs

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Lappe 2007^52^ Nebraska, US (41° N) [17556697] | - Health status; - Mean age (SD), y; - Male(%) | Mentally and physically fit; post-menopause67 (7.3) 0 | 25(OH)D: 71.8 nmol/L | Vit D_3_ 1000 IU/d + Ca (citrate 1400 mg/d or carbonate 1500 mg/d) vs. Ca (citrate 1400 mg/d or carbonate 1500 mg/d) vs. placebo | nd
Trivedi 2003^44^ Oxford, UK (52°N) [12609940] | - Health status; - Mean age(range), y; - Male (%) | General population 75 (65–85) 76% | 25(OH)D: 53.4 nmol/L Calcium intake=742 mg/d (at 4 years, no difference by treatment allocation) | Vit D_3_ 100,000 IU vs placebo every 4 months | Participants taking ≥80% of study medication: 76%^A^ | Previous CVD: 28%, previous cancer: 6%, steroids user: 5%, and HRT taker: 7%

A No difference between the vitamin D and the placebo arm.

Table 15 Vitamin D and total cancer: Characteristics of cohort studies

Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV exposure | Lifestyle | Comments
Cohort
Freedman2007^53^ NHANES III US (various) [16481636] | - Health status; - Mean age (range), y; - Male (%) | Any 44 (≥17) 45 | Assay methodSeason blood drawn | RIA (DiaSorin) All | Cancer mortality stratified by prespecified baseline25(OH)D cut points | X | X | X | X | X | X | Final model includes sex, race/ethnicity, and smoking pattern. Other potential confounders were examined but not chosen.
Melamed2008^47^ NHANES III US (various) [18695076] | - Health status; - Mean age (range), y; - Male (%) | DM 7.4%, history of CVD 7.9%, HTN 25% 45 (≥20) 46 | Assay methodSeason blood drawn | RIA (DiaSorin) All | Cancer mortality stratified by baseline 25(OH)D quartiles | X | X | X | X | X | X

Table 16 Vitamin D and total cancer: Results of RCTs

Author Year Study Name Location (Latitude) [PMID] | Life Stage | Outcome | 1°/2° | Followup, y | Interventions, Daily Dose | n Event | N Total | Outcome Metric (Comparison) | Result | 95% CI | P Btw | Study Quality
Lappe2007^52^ Nebraska, US (41° N) [17556697] | Post-menopausal women | Incident cancer (all causes) | 2° | 4 | Vit D_3_ 1000 IU + Ca (citrate 1400 mg or carbonate 1500 mg) | 13 | 446 | RR (Vit D+Ca vs Ca) | 0.76 | 0.38, 1.55 | NS | B
Lappe2007^52^ Nebraska, US (41° N) [17556697] | Post-menopausal women | Incident cancer (all causes) | 2° | 4 | Ca (citrate 1400 mg or carbonate 1500 mg) | 17 | 445 | | | | | B
Lappe2007^52^ Nebraska, US (41° N) [17556697] | Post-menopausal women | Incident cancer (restricted to subjects who were free of cancer at 1 y intervention) | 2° | 4 | Vit D_3_ 1000 IU + Ca (citrate 1400 mg or carbonate 1500 mg) | 8 | 403 | RR (Vit D+Ca vs Ca) | 0.55 | 0.24,1.28 | NS | B
Lappe2007^52^ Nebraska, US (41° N) [17556697] | Post-menopausal women | Incident cancer (restricted to subjects who were free of cancer at 1 y intervention) | 2° | 4 | Ca (citrate 1400 mg or carbonate 1500 mg) | 15 | 416 | | | | | B
Trivedi 2003^44^ [12609940] | 65–85 y, Both sexes | Incident cancer (all causes) | 2° | 5 | Vit D_3_100,000 IU every 4 mo (~833 IU/d) | 188 | 1345 | HR (Vit D vs placebo) | 1.09 | 0.86, 1.36 | NS | B
Trivedi 2003^44^ [12609940] | 65–85 y, Both sexes | Incident cancer (all causes) | 2° | 5 | Placebo | 173 | 1341 | | | | | B
Trivedi 2003^44^ [12609940] | | Total cancer mortality | 2° | 5 | Vit D_3_100,000 IU every 4 mo (~833 IU/d) | 63 | 1345 | HR (Vit D vs placebo) | 0.86 | 0.61, 1.2 | NS
Trivedi 2003^44^ [12609940] | | Total cancer mortality | 2° | 5 | Placebo | 72 | 1341

Table 17 Vitamin D and total cancer: Results of cohort studies

Author Year Study Name [PMID] | Life Stage | Outcome (n/N; Incidence) | Followup Duration (Time to Dx) | 25(OH)D, nmol/L | No. of Cases | No. in Category | Adjusted HR | 95% CI | P for Trend | Study Quality
Freedman 2007^53^ NHANES III US [16481636] | Adults, both sexes | Cancer mortality (536/16818; 0.032) | 105 mo | <50 | 175 | 5744 | 1 | Reference | 0.65 | B
Freedman 2007^53^ NHANES III US [16481636] | Adults, both sexes | Cancer mortality (536/16818; 0.032) | 105 mo | 50 to <62.5 | 103 | 3143 | 1.22 | 0.91, 1.64 | 0.65 | B
Freedman 2007^53^ NHANES III US [16481636] | Adults, both sexes | Cancer mortality (536/16818; 0.032) | 105 mo | 62.5 to <80 | 117 | 3713 | 1.02 | 0.69, 1.50 | 0.65 | B
Freedman 2007^53^ NHANES III US [16481636] | Adults, both sexes | Cancer mortality (536/16818; 0.032) | 105 mo | 80 to <100 | 80 | 4218 (total, ≥80 nmol/L) | 1.00 | 0.71, 1.40 | 0.65 | B
Freedman 2007^53^ NHANES III US [16481636] | Adults, both sexes | Cancer mortality (536/16818; 0.032) | 105 mo | 100 to<120 | 41 | | 0.92 | 0.58, 1.46 | 0.65 | B
Freedman 2007^53^ NHANES III US [16481636] | Adults, both sexes | Cancer mortality (536/16818; 0.032) | 105 mo | ≥120 | 20 | | 1.49 | 0.85, 2.64 | 0.65 | B
Freedman 2007^53^ NHANES III US [16481636] | Adults, males | Cancer mortality (318/7632; 0.042) | 105 mo | <50 | 88 | 1993 | 1 | Reference | 0.08 | B
Freedman 2007^53^ NHANES III US [16481636] | Adults, males | Cancer mortality (318/7632; 0.042) | 105 mo | 50 to <62.5 | 57 | 1461 | 1.03 | 0.73, 1.44 | 0.08 | B
Freedman 2007^53^ NHANES III US [16481636] | Adults, males | Cancer mortality (318/7632; 0.042) | 105 mo | 62.5 to <80 | 71 | 1845 | 0.99 | 0.57, 1.74 | 0.08 | B
Freedman 2007^53^ NHANES III US [16481636] | Adults, males | Cancer mortality (318/7632; 0.042) | 105 mo | 80 to <100 | 58 | 2333 (total, ≥80 nmol/L) | 1.21 | 0.83, 1.78 | 0.08 | B
Freedman 2007^53^ NHANES III US [16481636] | Adults, males | Cancer mortality (318/7632; 0.042) | 105 mo | ≥100 | 44 | | 1.35 | 0.78, 2.31 | 0.08 | B
Freedman 2007^53^ NHANES III US [16481636] | Adults, females | Cancer mortality (218/9163; 0.024) | 105 mo | <50 | 87 | 3751 | 1 | Reference | 0.12 | B
Freedman 2007^53^ NHANES III US [16481636] | Adults, females | Cancer mortality (218/9163; 0.024) | 105 mo | 50 to <62.5 | 46 | 1682 | 1.40 | 0.94, 2.08 | 0.12 | B
Freedman 2007^53^ NHANES III US [16481636] | Adults, females | Cancer mortality (218/9163; 0.024) | 105 mo | 62.5 to <80 | 46 | 1845 | 1.02 | 0.62, 1.67 | 0.12 | B
Freedman 2007^53^ NHANES III US [16481636] | Adults, females | Cancer mortality (218/9163; 0.024) | 105 mo | 80 to <100 | 22 | 1885 (total, ≥80 nmol/L) | 0.72 | 0.40, 1.26 | 0.12 | B
Freedman 2007^53^ NHANES III US [16481636] | Adults, females | Cancer mortality (218/9163; 0.024) | 105 mo | ≥100 | 17 | | 0.78 | 0.40, 1.53 | 0.12 | B
Melamed 2008^47^ NHANES III US (various) [18695076] | Adults, both sexes | Cancer mortality (N=13331) | Median 8.7 (IQR 7.1–10.2) y | >80 | nd | nd | 1 | Reference | nd | C
Melamed 2008^47^ NHANES III US (various) [18695076] | Adults, both sexes | Cancer mortality (N=13331) | Median 8.7 (IQR 7.1–10.2) y | 61–80 | nd | nd | 0.8 | 0.54, 1.19 | nd | C
Melamed 2008^47^ NHANES III US (various) [18695076] | Adults, both sexes | Cancer mortality (N=13331) | Median 8.7 (IQR 7.1–10.2) y | 44–60 | nd | nd | 1.08 | 0.8, 1.46 | nd | C
Melamed 2008^47^ NHANES III US (various) [18695076] | Adults, both sexes | Cancer mortality (N=13331) | Median 8.7 (IQR 7.1–10.2) y | <44 | nd | nd | 0.91 | 0.63, 1.31 | nd | C

* Statistically significant (P<0.05)

A 4-year population-based RCT,52 sampled from a 9 county, largely rural area in eastern Nebraska (latitude 41°N), aimed to determine the efficacy of vitamin D_3_ (1000 IU/d) plus calcium (either calcium citrate 1400 mg/d or calcium carbonate 1500 mg/d) or calcium alone (either calcium citrate 1400 mg/d or calcium carbonate 1500 mg/d) compared to placebo in reducing fracture incident. Only the comparison between the combined vitamin D and calcium versus the calcium alone groups is discussed here. The other comparisons are described in the calcium and combined vitamin D and calcium sections. This study was rated methodological quality B. Incidence of cancer was a secondary outcome of this trial. A total of 1179 postmenopausal women, aged more than 55 years old, were randomized. The mean 25(OH)D concentration at baseline was 72 nmol/L. The relative risk of developing cancer at the end of study was 0.76 (95 percent CI: 0.38, 1.55). On the hypothesis that cancers diagnosed early in the study would have been present, although unrecognized on entry, the analyses were restricted to women who were free of cancer at 1 year intervention. The relative risk of developing cancer at the end of study for the vitamin D_3_ plus calcium group changed to 0.55 (95 percentCI 0.24, 1.28).

Another 5-year RCT compared the effects of supplemental vitamin D_3_ (100,000 IU every 4 months) with placebo on total cancer mortality and incidence in 2686 elderly participants with a mean age of 75 years in the United Kingdom (latitude 52° N).44 Total cancer mortality and incidence were evaluated as two of multiple secondary endpoints. The primary endpoint was the prevention of fracture. At 5 years vitamin D_3_ supplementation had no significant effect on the prevention of total cancer mortality (HR 0.86; 95 percent CI 0.61, 1.20) or incidence (HR 1.09; 95 percent CI 0.86, 1.36). This trial was rated B because it did not report in sufficient detail the randomization method, and the outcome ascertainment was based on death certificates or self-reported data, not verified with another objective documents (e.g., medical records or pathology reports).

Reported in two publications (one was rated B and one was rated C), there was no association between baseline 25(OH)D concentrations and total cancer mortality in the total NHANES III study population47,53 or in subgroup analyses by either season or latitude after a median 9 years of followup.53

Findings by age, sex and/or ethnicity

There were no differences in the total cancer mortality and incidence between men and women, reported in a 5-year RCT compared the effects of supplemental vitamin D_3_ (100,000 IU every 4 months) with placebo. In the NHANES III analysis, there was a suggestion of increased risk of total cancer mortality in men whose baseline 25(OH)D were in the two highest categories (80 to <100 nmol/L;≥100 nmol/L) compared to the reference category (<50 nmol/L) [80 to <100 nmol/L: RR = 1.21, 95 percent CI 0.83 to 1.78;≥100 nmol/L: RR = 1.35; 95 percent CI 0.78 to 2.31; P for trend=0.08]. However, this relationship was not seen in women (P for trend=0.12).53 When racial/ethnic groups were considered separately, there was also no association between baseline 25(OH)D concentrations and total cancer mortality in non-Hispanic whites (P for trend=0.80), non-Hispanic blacks (P for trend=0.14), or Mexican Americans (P for trend=0.37).

Findings by life stage

- 0 – 6 mo No data
- 7 mo – 2 y No data
- 3 – 8 y No data
- 9 – 18 y No data
- 19 – 50 y Analyses using NAHANES III data showed no significant association between baseline 25(OH)D concentrations and total cancer mortality. NHANES III included participants mostly within this life stage.
- 51 – 70 y A proportion of participants in NHANES III were in this life stage, but no unique conclusions are possible for this life stage separate from those for people 19 to 50 years.
- ≥71 y One RCT included elderly men and women mostly in this life stage. The trial found no difference in total cancer mortality or incidence between supplemental vitamin D_3_ (100,000 IU every 4 months) and placebo.
- Postmenopause One RCT with healthy postmenopausal women showed no effect of vitamin D_3_ supplementation (1000 IU/d) on the risk of total cancer.
- Pregnant & lactating women No Data

#### Prostate cancer

Synopsis

No qualified systematic reviews have evaluated the association between serum vitamin D concentrations and incidence of prostate cancer. Eight nested case-control studies (2B, 6C) found no association between baseline serum 25(OH)D concentrations and the risk of prostate cancer. One study rated C found a significant association between lower baseline serum 25(OH)D concentrations (<30 compared to >55 nmol/L) and higher risk of prostate cancer (adjusted OR 1.8, lowest compared to highest quartile). The same study found that the prostate cancer risk was increased in subjects less than 52 years at study entry and who had serum 25(OH)D concentration less than 40 nmol/L (adjusted OR 3.5). However, there was no difference in risk between low and high serum 25(OH)D concentration for those older than 51 years at study entry. A C study suggested an U-shaped association between baseline serum 25(OH)D concentrations and the risk of prostate cancer.

Detailed presentation

(Tables 18 & 19; Figure 7)

Table 18 Vitamin D and prostate cancer: Characteristics of nested case-control studies

Author Year Study Name Location (Latitude) [PMID] | Population | | 25(OH)D | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Study Name Location (Latitude) [PMID] | Population | | 25(OH)D | | Comparisons | Nutrients | Demographic | Anthrop | Medical | UV exposure | Life styles | Comments
Ahn 2008^54^ PLCO US (21°N to 44°N) [18505967] | Health status Mean age (range/SD), y Male (%) | 8% current smoker 67.8 (5.3) 100 | Assay Season blood drawn | RIA (Heartland) nd | Prostate cancer risk stratified by baseline 25(OH)D quintiles | X | | X | X | | X
Platz 2004^63^ Mikhak 2007^61^ HPFS US (multiple latitudes) [15090720] [17440943] | Health status Mean age (range/SD), y Male (%) | Smoked 18%; DM 3.6% 66 (7) 100 | Assay Season blood drawn | RIA nd | Prostate cancer risk stratified by baseline 25(OH)D quartiles | X | X | X | X | X | X | 6% nonwhite
Freedman 2007^53^ NHANES III US (multiple latitudes) [17971526] | Health status Mean age (range/SD), y Male (%) | 28% current smoker 44 100 | Assay Season blood drawn | RIA South: Nov to Mar; North: Apr to Oct | Prostate cancer mortality stratified by 2 baseline 25(OH)D categories | X | X | X | X | X | X | 71% white; 14% black; 6% Hispanics
Tuohimaa 2004^64^ Helsinki Heart Vasterbotten; Janus Project; Finland (60°N) [14618623] | Health status Mean age (range/SD), y Male (%) | Gemfibrozil vs. placebo subjects <40 to >60 100 | Assay Season blood drawn | RIA (Incstar) nd | Prostate cancer risk stratified by 5 baseline 25(OH)D categories | | X | | | X
Li 2007^60^ Gann 1996^66^ PHS US (multiple latitudes) [17388667] [8850273] | Health status Mean age (range/SD), y Male (%) | on ASA, β-carotene, placebo trial; 9% current smoker 58.9 (8.3) 100 | Assa Season blood drawn Assay Season blood drawn | RIA (Bruce Hollis) 24% spring or winter | Prostate cancer risk stratified by baseline 25(OH)D quartiles | | X | | | | X | 94% white
Corder 1993^58^ San Francisco US (37°N) [8220092] | Health status Mean age (range/SD), y Male (%) | nd 57 (38–81) 100 | Assay Season blood drawn | Competitive protein-binding (Haddad, 1971) nd | Prostate cancer risk compared by baseline 25(OH)D | | X | | | X | | 50% black; 50% white
Ahonen 2000^55^ Helsinki Heart Finland (60°N) [11075874] | Health status Mean age (range/SD), y Male (%) | Gemfibrozil vs. placebo subjects 40–57 100 | Assay Season blood drawn | RIA (Incstar) Jan-Feb; Mar-May; Sep | Prostate cancer risk stratified by baseline 25(OH)D quartiles | | X | X | X | X | X
Nomura 1998^62^ Honolulu Heart US (21°N) [9794175] | Health status Mean age (range/SD), y Male (%) | 64% smoked 58 (49–70) 100 | Assay Season blood drawn | Protein-binding nd | Prostate cancer risk stratified by baseline 25(OH)D quartiles | | X | | | X | X | 100% Japanese Americans
Tuohimaa 2007^65^ Helsinki Heart Finland (60°N) 17301263 | Health status Mean age (range/SD), y Male (%) | Gemfibrozil vs. placebo subjects,br>51 (3.7) 100 | Assay Season blood drawn | RIA (Incstar) Most in winter | Prostate cancer risk stratified by 3 baseline 25(OH)D categories | | X | X | X
Jacobs 2004^59^ NPC Eastern US (25°46’N to 41°N) [15225833] | Health status Mean age (range/SD), y Male (%) | Selenium vs. placebo subjects^A^ 68 (nd) 100 | Assay Season blood drawn | RIA nd | Prostate cancer risk stratified by baseline 25(OH)D tertiles | | X | X | X | X | X
Braun 1995^57^ WCC, MD US (39°N) [7612803] | Health status Mean age (range/SD), y Male (%) | nd <45–75+ 100 | Assay Season blood drawn | RIA (Bruce Hollis, 1993) Aug through Nov | Prostate cancer risk stratified by baseline 25(OH)D quintiles | | X | | | | | 100% white
Baron 2005^56^ CPP US (multiple latitudes) [15767334]^B^ | Health status Mean age (range/SD), y Male (%) | had >1 colon adenoma removal 62 (8.7) 100 | Assay Season blood drawn | Competitive protein-binding (Quest) nd | Prostate cancer risk stratified by baseline 25(OH)D tertiles | X | X | | | X | | 5% black
Braun 1995^57^ WCC, MD US (39°N) [7612803] | Health status Mean age (range/SD), y Male (%) | nd <45–75+ 100 | Assay Season blood drawn | RIA (Bruce Hollis, 1993) Aug through Nov | Prostate cancer risk stratified by baseline 25(OH)D quintiles | | X | | | | | 100% white
Baron 2005^56^ CPP US (multiple latitudes) [15767334]^B^ | Health status Mean age (range/SD), y Male (%) | had >1 colon adenoma removal 62 (8.7) 100 | Assay Season blood drawn | Competitive protein-binding (Quest) nd | Prostate cancer risk stratified by baseline 25(OH)D tertiles | X | X | | | X | | 5% black

A For prevention of recurrence of non-melanoma skin cancer

B This is a cohort study, not a nested case-control study.

Table 19 Vitamin D and prostate cancer: Results of nested case-control studies

Author Year Study Name PMID | Life Stage (male), y | Outcome (no. of cases; no. of control) | Time to diagnosis, y | 25(OH)D concentration, nmol/L | No of cases | No. of control | Adjusted OR | 95% CI | P for trend | Study Quality
Ahn 2008^54^ PLCO [8505967] | 51–70 | Prostate cancer (741; 781) | 2–8 | 12.8–42.5 | 119 | 157 | 1 | Reference | 0.20 | B
Ahn 2008^54^ PLCO [8505967] | 51–70 | Prostate cancer (741; 781) | 2–8 | 42.5–51. | 125 | 156 | 1.10 | 0.78, 1.56 | 0.20 | B
Ahn 2008^54^ PLCO [8505967] | 51–70 | Prostate cancer (741; 781) | 2–8 | 51.4–60.5 | 190 | 157 | 1.53 | 1.10, 2.13^*^ | 0.20 | B
Ahn 2008^54^ PLCO [8505967] | 51–70 | Prostate cancer (741; 781) | 2–8 | 60.6–71.7 | 167 | 156 | 1.33 | 0.95, 1.86 | 0.20 | B
Ahn 2008^54^ PLCO [8505967] | 51–70 | Prostate cancer (741; 781) | 2–8 | 71.8–129.5 | 148 | 155 | 1.18 | 0.83, 1.68 | 0.20 | B
Platz 2004^63^ Mikhak 2007^61^ HPFS [15090720] [17440943] | 51–70 | Prostate cancer (460; 460) | 2.2 (mean) | Quartile 1^A^ | 109 | 114 | 1 | Reference | 0.59 | B
Platz 2004^63^ Mikhak 2007^61^ HPFS [15090720] [17440943] | 51–70 | Prostate cancer (460; 460) | 2.2 (mean) | Quartile 2 | 115 | 113 | 1.00 | 0.67, 1.49 | 0.59 | B
Platz 2004^63^ Mikhak 2007^61^ HPFS [15090720] [17440943] | 51–70 | Prostate cancer (460; 460) | 2.2 (mean) | Quartile 3 | 94 | 120 | 0.77 | 0.51, 1.15 | 0.59 | B
Platz 2004^63^ Mikhak 2007^61^ HPFS [15090720] [17440943] | 51–70 | Prostate cancer (460; 460) | 2.2 (mean) | Quartile 4 | 142 | 113 | 1.19 | 0.79, 1.79 | 0.59 | B
Freedman 2007^53^ NHANES III [17971526] | 19–50 | Mortality prostate cancer | nd | <62.5 | 22 | nd | 1 | Reference | 0.95 | B
Freedman 2007^53^ NHANES III [17971526] | 19–50 | Mortality prostate cancer | nd | ≥62.5 | 25 | nd | 0.91 | 0.39, 2.14 | 0.95 | B
Tuohimaa 2004^64^ Helsinki Heart [14618623] | 19–50 51–70 | Prostate cancer (622; 1451) | ≤9–>14 (range) | 19 | 19 | nd | 1.5 | 0.8, 2.7 | | C
Tuohimaa 2004^64^ Helsinki Heart [14618623] | 19–50 51–70 | Prostate cancer (622; 1451) | ≤9–>14 (range) | 20–39 | 169 | nd | 1.3 | 0.98, 1.6 | | C
Tuohimaa 2004^64^ Helsinki Heart [14618623] | 19–50 51–70 | Prostate cancer (622; 1451) | ≤9–>14 (range) | 40–59 | 229 | nd | 1 | Reference | | C
Tuohimaa 2004^64^ Helsinki Heart [14618623] | 19–50 51–70 | Prostate cancer (622; 1451) | ≤9–>14 (range) | 60–79 | 138 | nd | 1.2 | 0.9, 1.5 | | C
Tuohimaa 2004^64^ Helsinki Heart [14618623] | 19–50 51–70 | Prostate cancer (622; 1451) | ≤9–>14 (range) | ≥80 | 67 | nd | 1.7 | 1.1, 2.4^*^ | | C
Li 2007^60^ PHS [17388667] | 19–50 51–70 | Prostate cancer (492; 664) | 11 (median) | Quartile 1^B^ | nd | nd | 1.01 | 0.71, 1.44 | 0.91 | C
Li 2007^60^ PHS [17388667] | 19–50 51–70 | Prostate cancer (492; 664) | 11 (median) | Quartile 2 | nd | nd | 1.26 | 0.89, 1.80 | 0.91 | C
Li 2007^60^ PHS [17388667] | 19–50 51–70 | Prostate cancer (492; 664) | 11 (median) | Quartile 3 | nd | nd | 1.00 | 0.71, 1.41 | 0.91 | C
Li 2007^60^ PHS [17388667] | 19–50 51–70 | Prostate cancer (492; 664) | 11 (median) | Quartile 4 | nd | nd | 1 | Reference | 0.91 | C
Gann 1996^66^ PHS [8850273] | 19–50 51–70 | Prostate cancer (232; 414) | 6 (mean) | 15.7–53.3 | nd | nd | 1.00 | nd | 0.82 | C
Gann 1996^66^ PHS [8850273] | 19–50 51–70 | Prostate cancer (232; 414) | 6 (mean) | 53.4–70.9 | nd | nd | 1.10 | nd | 0.82 | C
Gann 1996^66^ PHS [8850273] | 19–50 51–70 | Prostate cancer (232; 414) | 6 (mean) | 71–93.5 | nd | nd | 1.16 | nd | 0.82 | C
Gann 1996^66^ PHS [8850273] | 19–50 51–70 | Prostate cancer (232; 414) | 6 (mean) | 93.6–194 | nd | nd | 0.92 | 0.56, 1.50 | 0.82 | C
Gann 1996^66^ PHS [8850273] | 19–50 51–70 | Prostate cancer; age ≤61 y | | 15.7–53.3 | nd | nd | 1.00 | nd | nd | C
Gann 1996^66^ PHS [8850273] | 19–50 51–70 | Prostate cancer; age ≤61 y | | 53.4–70.9 | nd | nd | 1.19 | nd | nd | C
Gann 1996^66^ PHS [8850273] | 19–50 51–70 | Prostate cancer; age ≤61 y | | 71–93.5 | nd | nd | 1.75 | nd | nd | C
Gann 1996^66^ PHS [8850273] | 19–50 51–70 | Prostate cancer; age ≤61 y | | 93.6–194 | nd | nd | 1.48 | 0.73, 2.98 | nd | C
Gann 1996^66^ PHS [8850273] | 19–50 51–70 | Prostate cancer; age >61 y | | 15.7–53.3 | nd | nd | 1.00 | nd | nd | C
Gann 1996^66^ PHS [8850273] | 19–50 51–70 | Prostate cancer; age >61 y | | 53.4–70.9 | nd | nd | 1.00 | nd | nd | C
Gann 1996^66^ PHS [8850273] | 19–50 51–70 | Prostate cancer; age >61 y | | 71–93.5 | nd | nd | 0.82 | nd | nd | C
Gann 1996^66^ PHS [8850273] | 19–50 51–70 | Prostate cancer; age >61 y | | 93.6–194 | nd | nd | 0.76 | 0.39, 1.47 | nd | C
Corder 1993^58^ [8220092] | 19–50 51–70 | Prostate cancer (181; 181) | >5 (mode) | 60.0 (case) vs. 50.5 (control) (est.) | 181 | 181 | - | - | - | C
Corder 1993^58^ [8220092] | 19–50 51–70 | Mortality prostate cancer | | nd | 51 | nd | - | - | - | C
Ahonen 2000^55^ Helsinki Heart [11075874] | 19–50 51–70 | Prostate cancer (149; 566) | 8–14 (mode) | < 30^C^ | 48 | 131 | 1.8 | 1.0, 3.2^*^ | 0.01 | C
Ahonen 2000^55^ Helsinki Heart [11075874] | 19–50 51–70 | Prostate cancer (149; 566) | 8–14 (mode) | 31–40 | 41 | 143 | 1.4 | 0.8, 2.4 | 0.01 | C
Ahonen 2000^55^ Helsinki Heart [11075874] | 19–50 51–70 | Prostate cancer (149; 566) | 8–14 (mode) | 41–54 | 26 | 148 | 0.8 | 0.5, 1.5 | 0.01 | C
Ahonen 2000^55^ Helsinki Heart [11075874] | 19–50 51–70 | Prostate cancer (149; 566) | 8–14 (mode) | > 55 | 34 | 144 | 1 | Reference | 0.01 | C
Ahonen 2000^55^ Helsinki Heart [11075874] | 19–50 51–70 | Prostate cancer in those <52 years old at entry | | ≤40 | nd | nd | 3.5 | 1.7, 7.0^*^ | | C
Ahonen 2000^55^ Helsinki Heart [11075874] | 19–50 51–70 | Prostate cancer in those <52 years old at entry | | >40 | nd | nd | 1 | | | C
Ahonen 2000^55^ Helsinki Heart [11075874] | 19–50 51–70 | Prostate cancer in those >51 years old at entry | | ≤40 | nd | nd | 1.2 | 0.7, 2.1 | | C
Ahonen 2000^55^ Helsinki Heart [11075874] | 19–50 51–70 | Prostate cancer in those >51 years old at entry | | >40 | nd | nd | 1 | | | C
Nomura 1998^62^ Honolulu Heart [9794175] | 19–50 51–70 | Prostate cancer (136; 136) | 16 (mean) | <85^D^ | 38 | 34 | 1 | Reference | 0.68 | C
Nomura 1998^62^ Honolulu Heart [9794175] | 19–50 51–70 | Prostate cancer (136; 136) | 16 (mean) | 85–101 | 35 | 36 | 0.8 | 0.4, 1.8 | 0.68 | C
Nomura 1998^62^ Honolulu Heart [9794175] | 19–50 51–70 | Prostate cancer (136; 136) | 16 (mean) | 102–119 | 30 | 32 | 0.8 | 0.4, 1.7 | 0.68 | C
Nomura 1998^62^ Honolulu Heart [9794175] | 19–50 51–70 | Prostate cancer (136; 136) | 16 (mean) | ≥120 | 33 | 34 | 0.8 | 0.4, 1.8 | 0.68 | C
Tuohimaa 2007^65^ Helsinki Heart [17301263] | 19–50 51–70 | Prostate cancer (132; 456) | 10.8 (mean) | <40 | - | - | 1.88 | 1.15, 3.08^*^ | | C
Tuohimaa 2007^65^ Helsinki Heart [17301263] | 19–50 51–70 | Prostate cancer (132; 456) | 10.8 (mean) | 40–59 | - | - | 1 | Reference | | C
Tuohimaa 2007^65^ Helsinki Heart [17301263] | 19–50 51–70 | Prostate cancer (132; 456) | 10.8 (mean) | ≥60 | - | - | 1.25 | 0.64, 2.43 | | C
Jacobs 2004^59^ NPC [15225833] | 51–70 | Prostate cancer (83; 166) | 5.1 (mean) | 20–63.3 | 26 | 58 | 1 | Reference | 0.51 | C
Jacobs 2004^59^ NPC [15225833] | 51–70 | Prostate cancer (83; 166) | 5.1 (mean) | 63.4–81.9 | 33 | 49 | 1.71 | 0.68, 4.34 | 0.51 | C
Jacobs 2004^59^ NPC [15225833] | 51–70 | Prostate cancer (83; 166) | 5.1 (mean) | 82–149 | 24 | 59 | 0.75 | 0.29, 1.91 | 0.51 | C
Braun 1995^57^ WCC [7612803] | 19–50 51–70 | Prostate cancer (61; 122) | 14 (mean) | <60.1 | 7 | 24 | 1 | Reference | 0.60 | C
Braun 1995^57^ WCC [7612803] | 19–50 51–70 | Prostate cancer (61; 122) | 14 (mean) | 60.1–73.8 | 17 | 25 | 2.3 | 0.7, 7.8 | 0.60 | C
Braun 1995^57^ WCC [7612803] | 19–50 51–70 | Prostate cancer (61; 122) | 14 (mean) | 73.9–88.5 | 16 | 24 | 2.3 | 0.7, 7.7 | 0.60 | C
Braun 1995^57^ WCC [7612803] | 19–50 51–70 | Prostate cancer (61; 122) | 14 (mean) | 88.6–103 | 4 | 25 | 0.6 | 0.1, 2.5 | 0.60 | C
Braun 1995^57^ WCC [7612803] | 19–50 51–70 | Prostate cancer (61; 122) | 14 (mean) | >103 | 17 | 24 | 2.4^E^ | 0.8, 8.2 | 0.60 | C
Baron 2005^56^ CPP [15767334]^F^ | 19–50 51–70 | Prostate cancer (70 cases in a total of 672)^F^ | <4 (34%) | <62.9 | nd | NA | 1 | Reference | 0.70 | C
Baron 2005^56^ CPP [15767334]^F^ | 19–50 51–70 | Prostate cancer (70 cases in a total of 672)^F^ | <4 (34%) | 62.9–84.9 | nd | NA | 1.22 | 0.66, 2.26 | 0.70 | C
Baron 2005^56^ CPP [15767334]^F^ | 19–50 51–70 | Prostate cancer (70 cases in a total of 672)^F^ | <4 (34%) | 85 | nd | NA | 0.32 | 0.72, 2.43 | 0.70 | C

* Statistically significant (P<0.05)

A Cut points separated by analytical run; season, distributions among control (see Table 3 in original study)

B Cut points based on control standardized by season of collection

C Cut points based on total original cohort

D Cut points based on control frequency

E Unadjusted

F This is a cohort study, not a nested case-control study

Figure 7 Prostate cancer risk stratified by vitamin D concentration

A total of 12 nested case-control studies in 14 publications reported on the association between baseline serum 25(OH)D concentrations and the risk of prostate cancer.53–66 The number of cases ranged from 61 to 749. The latitudes of the studies ranged from 21° N to 60° N. The mean age of the subjects ranged from 44 to 68 years. Baseline serum concentrations of 25(OH)D in these studies ranged from 12.8 to 194 nmol/L. The time between blood drawn and the diagnosis of prostate cancer varied from 2 to 16 years. The methodological quality of three studies was rated B and nine studies were rated C.

19–50 years

Two studies provided data on younger subjects. Ahonen et al. analyzed subjects from 40 to 57 years of age.55 The study found that the prostate cancer risk was increased in subjects less than 52 years at study entry and had low serum 25(OH)D concentration (≤40 nmol/L) (adjusted OR 3.5, 95% CI 1.7, 7.0). The corresponding adjusted OR for those older than 51 years at study entry was 1.2 and was not significant. This study adjusted for factors related to insulin resistance syndrome but not those potentially related to prostate cancer.

Freedman et al. analyzed data from NHANES III and reported on subjects with a mean age of 44 years and found that the adjusted relative risk of mortality from prostate cancer was 0.91 (95% CI 0.39, 2.14) in the group with baseline serum 25(OH)D concentration of at least 62.5 nmol/L compared to the group with less than 62.5 nmol/L.53

51–70 years

Ten studies reported data on subjects with a mean age ranged from 51 to 68 years. Eight studies did not find an association by trend analysis between baseline serum 25(OH)D concentrations and the risk of prostate cancer.54,56–63,66 One study found no association between baseline serum 25(OH)D concentrations and mortality from prostate cancer.58 One study found an association between lower baseline serum 25(OH)D concentrations (<30 compared to >55 nmol/L) and the risk of prostate cancer (P for trend = 0.01).55 The adjusted OR of the lowest compared to highest quartile was 1.8. The study also found that the prostate cancer risk was increased in subjects less than 52 years at study entry and had low serum 25(OH)D concentration (≤40 nmol/L) (adjusted OR 3.5, 95 percent CI 1.7, 7.0). However, there was no difference in risk (adjusted OR 1.2, P=NS) between low (≤40 nmol/L) and high (>40 nmol/L) serum 25(OH)D concentration for those older than 51 years at study entry. This study did not adjust for factors potentially relevant to prostate cancer. One study reported an U-shaped association between baseline serum 25(OH)D concentrations and the risk of prostate cancer: the odds ratio in the group with 25(OH)D concentration of at least 80 nmol/L was 1.7 (95 percent CI 1.1, 2.4) compared to the group with a 25(OH)D concentration of 40–49 nmol/L; the odds ratio in the group with 25(OH)D concentration of no more than 19 nmol/L was 1.5 (95 percent CI 0.8, 2.7) compared to the group with a 25(OH)D concentration of 40 to 49 nmol/L.64 Even though this study used a conditional logistic regression in its analysis to maintain matching status, it was unclear if additional factors potentially relevant to prostate cancer were also entered into the regression analysis.

1,25(OH)_2_D

Five studies reported on the association between 1,25(OH)_2_D serum concentrations and the risk of prostate cancer. Four studies did not find an association.59,62,63,66 One study found that the risk of prostate cancer decreased with higher serum concentrations of 1,25(OH)_2_D in men with low serum concentrations of 25(OH)D (unadjusted OR 0.15, comparing 4^th^ quartile of 1,25(OH)_2_D (104–211 pmol/L) to 1^st^ quartile (13–68 pmol/L) in men with serum 25(OH)D concentrations that ranged from 7.5–45 nmol/L).58 When stratified by age and race, this association was only found in men above the median age of 57 years at time of blood drawn but not in younger men; the association was similar in black and white men.

Findings by life stage

- 0–6 mo not applicable
- 7 mo – 2 y not applicable
- 3–8 y not applicable
- 9–18 y not reviewed
- 19–50 y One study found that the prostate cancer risk was highest in subjects less than 52 years at study entry and had low serum 25(OH)D concentration (≤40 nmol/L) (adjusted OR 3.5, 95 percent CI 1.7, 7.0). Another study analyzed data from NHANES III and reported on subjects with a mean age of 44 years and found that the adjusted relative risk of mortality from prostate cancer was 0.91 (95 percent CI 0.39, 2.14) in the group with baseline serum 25(OH)D concentration of at least 62.5 nmol/L compared to the group with less than 62.5 nmol/L.
- 51–70 y Eight studies did not find an association by P for trend analysis between baseline serum 25(OH)D concentrations and the risk of prostate cancer. One study found an inverse association of baseline serum 25(OH)D concentrations (<30 compared to >55 nmol/L) and the risk of prostate cancer (adjusted OR 1.8, lowest compared to highest quartile, P for trend = 0.01). This study found that the prostate cancer risk was increased in subjects less than 52 years at study entry and had low serum 25(OH)D concentration (≤40 nmol/L) (adjusted OR 3.5, 95 percent CI 1.7, 7.0). However, there was no difference in risk (adjusted OR 1.2, P=NS) between low (≤40 nmol/L) and high (>40 nmol/L) serum 25(OH)D concentration for those older than 51 years at study entry. One study reported an U-shaped association between baseline serum 25(OH)D concentrations and the risk of prostate cancer: the odds ratio in the group with 25(OH)D concentration of at least 80 nmol/L was 1.7 (95 percent CI 1.1, 2.4) compared to the group with a 25(OH)D concentration of 40–49 nmol/L; the odds ratio in the group with 25(OH)D concentration of no more than 19 nmol/L was 1.5 (95 percent CI 0.8, 2.7) compared to the group with a 25(OH)D concentration of 40 to 49 nmol/L.
- ≥71 y No study specifically targeted men older than 70 years.
- Postmenopause Not applicable
- Pregnant & lactating women Not applicable

#### Colorectal cancer

Synopsis

No qualified systematic reviews have evaluated the association between 25(OH)D concentrations and colorectal cancer mortality or incidence. One B quality RCT of elderly population reported no significant difference in colorectal cancer mortality or incidence between supplemental vitamin D_3_ and no supplements. One B quality cohort study found an inverse association between higher 25(OH)D concentrations and the risk of colorectal cancer mortality (HR 0.28, highest compared to lowest tertile). Two B quality nested case-control studies of women found a trend between higher 25(OH)D serum concentrations and lower risk of colorectal cancer incidence (trend analysis). Another two B quality nested case-control studies of men, and one B quality and two C quality nested case-control studies of both sexes reported no significant association between 25(OH)D concentrations and risk of colorectal cancer or colon cancer.

Detailed presentation of supplemental vitamin D and colorectal caner

(Tables 20 & 21)

Table 20 Vitamin D and colorectal cancer: Characteristics of RCTs

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Trivedi 2003^44^ Oxford, UK (52°N) [12609940] | - Health Status; - Mean age (range), y; - Male(%) | General population 75 (65–85) 76% | 25(OH)D: 53.4 nmol/L Calcium intake= 742 mg/day (at 4 years, no difference by treatment allocation) | Vit D_3_ 100,000 IU vs placebo every 4 months | Participants taking ≥80% of study medication: 76%^A^ | Previous CVD: 28%, previous cancer: 6%, steroids user: 5%, and HRT taker: 7%

CVD = cardiovascular disease; HRT = hormone replacement therapy.

A No difference between the vitamin D and the placebo arm.

Table 21 Vitamin D and colorectal cancer: Results of RCTs

Author Year Study Name [PMID] | Age Range, Sex (Subgp) | Outcome | 1°/2° | Mean Followup | Interventions, Daily Dose | n Event | N Total | Outcome Metric (Comparison) | Result | 95% CI | P Btw | Study Quality
Trivedi 2003^44^ [12609940] | 65–85 y, Both sexes | CRC, mortality | 2° | 5 y | Vit D_3_ 100,000 IU every 4 mo | 7 | 1345 | Age adj HR (Vit D/Placebo) | 0.62 | 0.24, 1.60 | 0.33 | B
Trivedi 2003^44^ [12609940] | 65–85 y, Both sexes | CRC, mortality | 2° | 5 y | Placebo | 11 | 1341 | | | | | B
Trivedi 2003^44^ [12609940] | 65–85 y, Both sexes | CRC, incidence | 2° | 5 y | Vit D_3_ | 28 | 1345 | Age adj HR (Vit D/Placebo) | 1.02 | 0.60, 1.74 | 0.94 | B
Trivedi 2003^44^ [12609940] | 65–85 y, Both sexes | CRC, incidence | 2° | 5 y | Placebo | 27 | 1341 | | | | | B
Trivedi 2003^44^ [12609940] | 65–85 y, Men | CRC, mortality | 2° | 5 y | Vit D_3_ | 7 | 1019 | Age adj HR (Vit D/Placebo) | 0.97 | 0.34, 2.78 | 0.96 | B
Trivedi 2003^44^ [12609940] | 65–85 y, Men | CRC, mortality | 2° | 5 y | Placebo | 7 | 1018 | | | | | B
Trivedi 2003^44^ [12609940] | 65–85 y, Men | CRC, incidence | 2° | 5 y | Vit D_3_ | 25 | 1019 | Age adj HR (Vit D/Placebo) | 1.18 | 0.65, 2.12 | 0.59 | B
Trivedi 2003^44^ [12609940] | 65–85 y, Men | CRC, incidence | 2° | 5 y | Placebo | 21 | 1018 | | | | | B
Trivedi 2003^44^ [12609940] | 65–85 y, Women | CRC, mortality | 2° | 5 y | Vit D_3_ | 0 | 326 | Age adj HR (Vit D/Placebo) | NA | NA | 0.04 | B
Trivedi 2003^44^ [12609940] | 65–85 y, Women | CRC, mortality | 2° | 5 y | Placebo | 4 | 323 | | | | | B
Trivedi 2003^44^ [12609940] | 65–85 y, Women | CRC, incidence | 2° | 5 y | Vit D_3_ | 3 | 326 | Age adj HR (Vit D/Placebo) | 0.49 | 0.12, 1.98 | 0.32 | B
Trivedi 2003^44^ [12609940] | 65–85 y, Women | CRC, incidence | 2° | 5 y | Placebo | 6 | 323 | | | | | B

An RCT compared supplemental vitamin D_3_ (100,000 IU every 4 months) with placebo in 2686 elderly participants with a mean age of 75 years in the United Kingdom (latitude 52° N). 44 Colorectal cancer mortality and incidence were evaluated as two of multiple secondary endpoints. The primary endpoint was the prevention of fracture. At 5 years vitamin D_3_ supplementation had no significant effect on the prevention of colorectal cancer mortality (P=0.33) or incidence (P=0.94). This trial was rated B because it did not report in sufficient detail the randomization method, and the outcome ascertainment was based on death certificates or self-reported data, not verified with another objective documents (e.g., medical records or pathology reports).

Findings per age and sex

The same British trial reported no significant difference in colorectal cancer mortality or incidence between the vitamin D supplements group and the placebo at 5 years in men (P=0.96 and 0.59, respectively). In women, the trial also found no significant difference in colorectal cancer incidence between the two groups (P=0.32), whereas the risk of colorectal cancer mortality in the supplements group was significantly decreased compared to the placebo (0/326 deaths vs. 4/323 deaths; HR, not reported; P=0.04).

Findings per special populations

No subgroup data were available regarding special populations (e.g., obese participants, smokers, ethnic groups, or users of contraceptives).

Detailed presentation of 25(OH)D concentrations and colorectal cancer

(Tables 22 & 23; Figures 8, 9, & 10)

Table 22 Vitamin D and colorectal cancer: Characteristics of observational studies^A^

Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV exposure | Lifestyle | Comments
Cohort
Freedman 2007^53^ NHANES III US (various) [16481636] | - Health status; - Mean age (range), y; - Male (%) | Any 44 (≥17) 45 | - Assay method; - Season blood drawn | RIA (DiaSorin) All | Colorectal cancer mortality stratified by prespecified baseline 25(OH)D cut points | X | X | X | X | X | X | White: 71%; Black: 14%; Hispanic: 6%; Others: 9%
Nested case-control
Braun 1995^73^ WCC Maryland, US (38°N) [329893] | - Health status; - Mean age (range), y; - Male (%) | Any 55 (nd) Nd | - Assay method; - Season blood drawn | RIA (Horris 1993) Fall | - 25(OH)D levels between cases and controls; - Colon cancer risk stratified by baseline 25(OH)D quintiles | | X | | | X
Feskanich 2004^70^ NHS US (various) [15342452] | - Health status; - Mean age (range), y; - Male (%) | Any 60 (43–70) 0 | - Assay method; - Season blood drawn | RIA (Horris 1997) All | Colorectal cancer risk stratified by baseline 25(OH)D quintiles | X | X | X | X | X | X | Aspirin user (>10 y): 10%; Hormone replacement therapy: 34%
Garland 1989^72^ WCC Maryland, US (38°N) [2572900] | - Health status; - Mean age (range), y; - Male (%) | Any 63 (nd) 50 | - Assay method; - Season blood drawn | HPLA Clemens 1982) Fall | - 25(OH)D levels between cases and controls; - Colon cancer risk stratified by baseline 25(OH)D quintiles | | X | | | X | | White: 100%
Otani 2007^68^ Japan PHC Japan (various) [17622244] | - Health status; - Mean age (range), y; - Male (%) | Any Men: 57 (40–69); Women: 56 (40–69) | - Assay method; - Season blood drawn | CPBA (Haddad 1971) All | - 25(OH)D levels between cases and controls; - Colon cancer risk stratified by baseline 25(OH)D quintiles | X | X | X | X | X | X
Tangrea 1997^67^ ATBC Finland (~60°N) [9242478] | - Health status; - Mean age (range), y; - Male (%) | Smoker^B^ 60 (50–69) 100 | - Assay method; - Season blood drawn | RIA (Horris 1993) All | Colorectal cancer risk stratified by baseline 25(OH)D quintiles | X | X | X | | X | X
Wactawski-Wende 2006^71^ WHI US (various) [16481636] | - Health status; - Mean age (range), y; - Male (%) | Post-menopausal women^C^ Nd (50–79) 0 | - Assay method; - Season blood drawn | RIA (DiaSorin) All | Colorectal cancer risk stratified by baseline 25(OH)D quintiles | | X | X | X | | X | White: 83%; Black: 9%; Hispanic 4% Others: 4%
Wu 2007^69^ HPFS US (various) [17623801] | - Health status; - Mean age (range), y; - Male (%) | Smoker 5% 66 (nd) 100 | - Assay method; - Season blood drawn | RIA (Horris 1997) All | - 25(OH)D levels between cases and controls; - Colon cancer risk stratified by baseline 25(OH)D quintiles | X | X | X | X | X | X | Aspirin user in 1994: 40%; Current smoker: 5%

A This table is ordered alphabetically by study author.

B Participants of a lung cancer prevention 2 by 2 RCT of alpha-tocopherol and beta-carotene.

C Participants of a hip fracture prevention RCT of vitamin D3 and calcium.

Table 23 Vitamin D and colorectal cancer: Results of observational studies

Author Year Study Name [PMID] | Life Stage | Outcome (n/N; Incidence) | Followup Duration (Time to Dx) | 25(OH)D Concentration, nmol/L | No. of Cases | No. in Category | Adjusted OR | 95% CI | P for Trend | Study Quality
Cohort study
Colorectal cancer mortality
Women
Freedman 2007^53^ [17971526] | 19–50^A^ 51–70 ≥71 | Colorectal Cancer Mortality (66/16818; 0.004) | nd | <50 | 28 | ~5606 | 1 | Reference | 0.02 | B
Freedman 2007^53^ [17971526] | 19–50^A^ 51–70 ≥71 | Colorectal Cancer Mortality (66/16818; 0.004) | nd | 50–80 | 24 | ~5606 | 0.44 | 0.20, 0.95^*^ | 0.02 | B
Freedman 2007^53^ [17971526] | 19–50^A^ 51–70 ≥71 | Colorectal Cancer Mortality (66/16818; 0.004) | nd | ≥80 | 14 | ~5606 | 0.28 | 0.11, 0.68^*^ | 0.02 | B
Nested case-control study
Colorectal cancer
Men
Otani 2007^68^ Japan PHC [17622244] | 19–50 51–70^A^ | Colorectal cancer (N=196 cases; 392 controls) | 1–13 | <57.2 | 43 | 74 | 1 | Reference | 0.39 | B
Otani 2007^68^ Japan PHC [17622244] | 19–50 51–70^A^ | Colorectal cancer (N=196 cases; 392 controls) | 1–13 | 57.2–69.0 | 40 | 85 | 0.76 | 0.42, 1.4 | 0.39 | B
Otani 2007^68^ Japan PHC [17622244] | 19–50 51–70^A^ | Colorectal cancer (N=196 cases; 392 controls) | 1–13 | 69.0–80.2 | 36 | 85 | 0.76 | 0.39, 1.5 | 0.39 | B
Otani 2007^68^ Japan PHC [17622244] | 19–50 51–70^A^ | Colorectal cancer (N=196 cases; 392 controls) | 1–13 | ≥80.2 | 44 | 80 | 0.73 | 0.35, 1.5 | 0.39 | B
Wu 2007^69^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Colorectal cancer (179 cases; 356controls) | 1–9 | 46, median | 45 | 71 | 1 | Reference | 0.24^B^ | B
Wu 2007^69^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Colorectal cancer (179 cases; 356controls) | 1–9 | 62.5 | 44 | 71 | 0.97 | 0.55, 1.70 | 0.24^B^ | B
Wu 2007^69^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Colorectal cancer (179 cases; 356controls) | 1–9 | 72.8 | 30 | 68 | 0.66 | 0.35, 1.24 | 0.24^B^ | B
Wu 2007^69^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Colorectal cancer (179 cases; 356controls) | 1–9 | 83.3 | 23 | 74 | 0.51 | 0.27, 0.97^*^ | 0.24^B^ | B
Wu 2007^69^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Colorectal cancer (179 cases; 356controls) | 1–9 | 98.5 | 37 | 72 | 0.83 | 0.45, 1.52 | 0.24^B^ | B
Wu 2007^69^ HPFS [17623801] | 19–50 51–70^A^ | Colorectal cancer, age <65 | | 48.2, median | 25 | 34 | 1 | Reference | 0.13 | B
Wu 2007^69^ HPFS [17623801] | 19–50 51–70^A^ | Colorectal cancer, age <65 | | 66.8 | 15 | 28 | 1.03 | 0.36, 2.91 | 0.13 | B
Wu 2007^69^ HPFS [17623801] | 19–50 51–70^A^ | Colorectal cancer, age <65 | | 80.0 | 9 | 30 | 0.38 | 0.12, 1.26 | 0.13 | B
Wu 2007^69^ HPFS [17623801] | 19–50 51–70^A^ | Colorectal cancer, age <65 | | 97.0 | 14 | 36 | 0.45 | 0.15, 1.40 | 0.13 | B
Wu 2007^69^ HPFS [17623801] | 51–70^A^ ≥71 | Colorectal cancer, age ≥65 | | 48.2, median | 34 | 55 | 1 | Reference | 0.34 | B
Wu 2007^69^ HPFS [17623801] | 51–70^A^ ≥71 | Colorectal cancer, age ≥65 | | 66.8 | 36 | 61 | 0.97 | 0.50, 1.87 | 0.34 | B
Wu 2007^69^ HPFS [17623801] | 51–70^A^ ≥71 | Colorectal cancer, age ≥65 | | 80.0 | 19 | 58 | 0.56 | 0.27, 1.15 | 0.34 | B
Wu 2007^69^ HPFS [17623801] | 51–70^A^ ≥71 | Colorectal cancer, age ≥65 | | 97.0 | 27 | 54 | 0.83 | 0.39, 1.75 | 0.34 | B
Tangrea 1997^67^ ATBC [9242478] | 19–50 51–70^A^ | Colorectal cancer (146 cases; 292 controls) | 1–8 | ≤24.5 | 46 | 72 | 1 | Reference | 0.13 | B
Tangrea 1997^67^ ATBC [9242478] | 19–50 51–70^A^ | Colorectal cancer (146 cases; 292 controls) | 1–8 | 24.5–34.7 | 35 | 73 | 0.7 | 0.4, 1.3 | 0.13 | B
Tangrea 1997^67^ ATBC [9242478] | 19–50 51–70^A^ | Colorectal cancer (146 cases; 292 controls) | 1–8 | 34.7–48.2 | 36 | 73 | 0.8 | 0.4, 1.3 | 0.13 | B
Tangrea 1997^67^ ATBC [9242478] | 19–50 51–70^A^ | Colorectal cancer (146 cases; 292 controls) | 1–8 | >48.2 | 29 | 72 | 0.6 | 0.3, 1.1 | 0.13 | B
Women
Wactawski-Wende 2006^71^ WHI [16481636] | Post-menopausal women | Colorectal cancer (306 cases; 306 controls) | 1–12 | <31.0 | 88 | 67 | 2.53 | 1.49, 4.32 | 0.02 | B
Wactawski-Wende 2006^71^ WHI [16481636] | Post-menopausal women | Colorectal cancer (306 cases; 306 controls) | | 31.0–42.3 | 80 | 73 | 1.96 | 1.18, 3.24^*^ | 0.02 | B
Wactawski-Wende 2006^71^ WHI [16481636] | Post-menopausal women | Colorectal cancer (306 cases; 306 controls) | | 42.4–58.3 | 78 | 73 | 1.95 | 1.18, 3.24^*^ | 0.02 | B
Wactawski-Wende 2006^71^ WHI [16481636] | Post-menopausal women | Colorectal cancer (306 cases; 306 controls) | | ≥58.4 | 60 | 93 | 1 | Reference | 0.02 | B
Feskanich 2004^70^ NHS [15342452] | 19–50 51–70^A^ | Colorectal cancer (192 cases; 384 controls) | 1–11 | 40.2, median | 53 | 77 | 1 | Reference | 0.02^C^ | B
Feskanich 2004^70^ NHS [15342452] | 19–50 51–70^A^ | Colorectal cancer (192 cases; 384 controls) | 1–11 | 55.1 | 47 | 79 | 0.93 | 0.53, 1.63 | 0.02^C^ | B
Feskanich 2004^70^ NHS [15342452] | 19–50 51–70^A^ | Colorectal cancer (192 cases; 384 controls) | 1–11 | 66.7 | 35 | 75 | 0.79 | 0.44, 1.40 | 0.02^C^ | B
Feskanich 2004^70^ NHS [15342452] | 19–50 51–70^A^ | Colorectal cancer (192 cases; 384 controls) | 1–11 | 77.5 | 29 | 77 | 0.58 | 0.31, 1.07 | 0.02^C^ | B
Feskanich 2004^70^ NHS [15342452] | 19–50 51–70^A^ | Colorectal cancer (192 cases; 384 controls) | 1–11 | 99.1 | 29 | 75 | 0.53 | 0.27, 1.04 | 0.02^C^ | B
Otani 2007^68^ Japan PHC [17622244] | 19–50 51–70^A^ | Colorectal cancer (179 cases; 358 controls) | 1–13 | <57.2 | 41 | 77 | 1 | Reference | 0.74 | B
Otani 2007^68^ Japan PHC [17622244] | 19–50 51–70^A^ | Colorectal cancer (179 cases; 358 controls) | 1–13 | 57.2–69.0 | 34 | 73 | 1.0 | 0.55, 1.9 | 0.74 | B
Otani 2007^68^ Japan PHC [17622244] | 19–50 51–70^A^ | Colorectal cancer (179 cases; 358 controls) | 1–13 | 69.0–80.2 | 44 | 71 | 1.2 | 0.65, 2.3 | 0.74 | B
Otani 2007^68^ Japan PHC [17622244] | 19–50 51–70^A^ | Colorectal cancer (179 cases; 358 controls) | 1–13 | ≥80.2 | 41 | 76 | 1.1 | 0.50, 2.3 | 0.74 | B
Colon cancer
Both sexes
Braun 1995^73^ WCC [329893] | 19–50 51–70^A^ ≥71 | Colon cancer (57 cases; 114 controls) | 1–17 | <43 | nd | nd | 1 | Reference | 0.57 | C
Braun 1995^73^ WCC [329893] | 19–50 51–70^A^ ≥71 | Colon cancer (57 cases; 114 controls) | 1–17 | 43.0–51.5 | nd | nd | 0.3 | 0.1, 1.0 | 0.57 | C
Braun 1995^73^ WCC [329893] | 19–50 51–70^A^ ≥71 | Colon cancer (57 cases; 114 controls) | 1–17 | 51.5–61.8 | nd | nd | 0.5 | 0.2, 1.5 | 0.57 | C
Braun 1995^73^ WCC [329893] | 19–50 51–70^A^ ≥71 | Colon cancer (57 cases; 114 controls) | 1–17 | 61.8–75.3 | nd | nd | 0.7 | 0.2, 2.0 | 0.57 | C
Braun 1995^73^ WCC [329893] | 19–50 51–70^A^ ≥71 | Colon cancer (57 cases; 114 controls) | 1–17 | ≥75.3 | nd | nd | 0.4 | 0.1, 1.4 | 0.57 | C
Garland 1989^72^ WCC [2572900] | 19–50 51–70^A^ 71 | Colon cancer (34 cases; 67 controls) | 1–9 | 10 to <50 | 9 | 8 | 1 | Reference | 0.41 | C
Garland 1989^72^ WCC [2572900] | 19–50 51–70^A^ 71 | Colon cancer (34 cases; 67 controls) | 1–9 | 50.0–67.5 | 7 | 13 | 0.48 | 0.13, 1.80 | 0.41 | C
Garland 1989^72^ WCC [2572900] | 19–50 51–70^A^ 71 | Colon cancer (34 cases; 67 controls) | 1–9 | 67.5–82.5 | 5 | 18 | 0.25 | 0.06, 0.98^*^ | 0.41 | C
Garland 1989^72^ WCC [2572900] | 19–50 51–70^A^ 71 | Colon cancer (34 cases; 67 controls) | 1–9 | 82.5–105 | 4 | 17 | 0.21 | 0.05, 0.89^*^ | 0.41 | C
Garland 1989^72^ WCC [2572900] | 19–50 51–70^A^ 71 | Colon cancer (34 cases; 67 controls) | 1–9 | 105–227.5 | 9 | 11 | 0.73 | 0.20, 2.66 | 0.41 | C
Men
Otani 2007^68^ Japan PHC [17622244] | 19–50 51–70^A^ | Colon cancer (141 cases; 282 controls) | 1–13 | <57.2 | 25 | 54 | 1 | Reference | 0.70 | B
Otani 2007^68^ Japan PHC [17622244] | 19–50 51–70^A^ | Colon cancer (141 cases; 282 controls) | 1–13 | 57.2–69.0 | 27 | 55 | 0.98 | 0.48, 2.0 | 0.70 | B
Otani 2007^68^ Japan PHC [17622244] | 19–50 51–70^A^ | Colon cancer (141 cases; 282 controls) | 1–13 | 69.0–80.2 | 29 | 66 | 1.0 | 0.48, 2.3 | 0.70 | B
Otani 2007^68^ Japan PHC [17622244] | 19–50 51–70^A^ | Colon cancer (141 cases; 282 controls) | 1–13 | ≥80.2 | 38 | 62 | 1.2 | 0.51, 2.7 | 0.70 | B
Wu 2007^69^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Colon cancer (139 cases; 276 controls) | 1–9 | 48.3, median | 49 | 66 | 1 | Reference | 0.005^D^ | B
Wu 2007^69^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Colon cancer (139 cases; 276 controls) | 1–9 | 66.8 | 44 | 68 | 0.74 | 0.42, 1.33 | 0.005^D^ | B
Wu 2007^69^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Colon cancer (139 cases; 276 controls) | 1–9 | 80.0 | 17 | 68 | 0.29 | 0.14, 0.59^*^ | 0.005^D^ | B
Wu 2007^69^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Colon cancer (139 cases; 276 controls) | 1–9 | 97.0 | 29 | 74 | 0.46 | 0.24, 0.89^*^ | 0.005^D^ | B
Tangrea 1997^67^ ATBC [9242478] | 19–50 51–70^A^ | Colon cancer (91cases; 182 controls) | 1–8 | ≤24.5 | 30 | 47 | 1 | Reference | 0.69^E^ | B
Tangrea 1997^67^ ATBC [9242478] | 19–50 51–70^A^ | Colon cancer (91cases; 182 controls) | 1–8 | 24.5–34.7 | 18 | 47 | 0.6 | 0.3, 1.2 | 0.69^E^ | B
Tangrea 1997^67^ ATBC [9242478] | 19–50 51–70^A^ | Colon cancer (91cases; 182 controls) | 1–8 | 34.7–48.2 | 22 | 45 | 0.8 | 0.4, 1.6 | 0.69^E^ | B
Tangrea 1997^67^ ATBC [9242478] | 19–50 51–70^A^ | Colon cancer (91cases; 182 controls) | 1–8 | >48.2 | 21 | 42 | 0.8 | 0.4, 1.6 | 0.69^E^ | B
Women
Feskanich 2004^70^ NHS [15342452] | 19–50 51–70^A^ | Colon cancer (148 cases; 296 controls) | 1–11 | 41.2, median | 41.2 | 75 | 1 | Reference | 0.17 | B
Feskanich 2004^70^ NHS [15342452] | 19–50 51–70^A^ | Colon cancer (148 cases; 296 controls) | 1–11 | 59.7 | 59.7 | 71 | 1.03 | 0.56, 1.89 | 0.17 | B
Feskanich 2004^70^ NHS [15342452] | 19–50 51–70^A^ | Colon cancer (148 cases; 296 controls) | 1–11 | 73.3 | 73.3 | 77 | 0.54 | 0.28, 1.03 | 0.17 | B
Feskanich 2004^70^ NHS [15342452] | 19–50 51–70^A^ | Colon cancer (148 cases; 296 controls) | 1–11 | 98.1 | 98.1 | 72 | 0.70 | 0.35, 1.38 | 0.17 | B
Otani 2007^68^ Japan PHC [17622244] | 19–50 51–70^A^ | Colon cancer (115 cases; 230 controls) | 1–13 | <57.2 | 21 | 53 | 1 | Reference | 0.12 | B
Otani 2007^68^ Japan PHC [17622244] | 19–50 51–70^A^ | Colon cancer (115 cases; 230 controls) | 1–13 | 57.2–69.0 | 27 | 48 | 1.7 | 0.78, 3.6 | 0.12 | B
Otani 2007^68^ Japan PHC [17622244] | 19–50 51–70^A^ | Colon cancer (115 cases; 230 controls) | 1–13 | 69.0–80.2 | 27 | 41 | 2.1 | 0.90, 4.7 | 0.12 | B
Otani 2007^68^ Japan PHC [17622244] | 19–50 51–70^A^ | Colon cancer (115 cases; 230 controls) | 1–13 | ≥80.2 | 31 | 53 | 2.1 | 0.78, 5.6 | 0.12 | B
Rectal cancer
Men
Otani 2007^68^ Japan PHC [17622244] | 19–50 51–70^A^ | Rectal cancer (55cases; 110 controls) | 1–13 | <57.2 | 18 | 20 | 1 | Reference | 0.06 | B
Otani 2007^68^ Japan PHC [17622244] | 19–50 51–70^A^ | Rectal cancer (55cases; 110 controls) | 1–13 | 57.2–69.0 | 13 | 30 | 0.17 | 0.02, 1.2 | 0.06 | B
Otani 2007^68^ Japan PHC [17622244] | 19–50 51–70^A^ | Rectal cancer (55cases; 110 controls) | 1–13 | 69.0–80.2 | 7 | 19 | 0.25 | 0.05, 1.3 | 0.06 | B
Otani 2007^68^ Japan PHC [17622244] | 19–50 51–70^A^ | Rectal cancer (55cases; 110 controls) | 1–13 | ≥80.2 | 6 | 18 | 0.075 | 0.005, 0.99 | 0.06 | B
Tangrea 1997^67^ ATBC [9242478] | 19–50 51–70^A^ | Rectal cancer (55cases; 110 controls) | 1–8 | le;24.5 | 16 | 25 | 1 | Reference | 0.06^F^ | B
Tangrea 1997^67^ ATBC [9242478] | 19–50 51–70^A^ | Rectal cancer (55cases; 110 controls) | 1–8 | 24.5–34.7 | 17 | 26 | 0.9 | 0.4, 2.4 | 0.06^F^ | B
Tangrea 1997^67^ ATBC [9242478] | 19–50 51–70^A^ | Rectal cancer (55cases; 110 controls) | 1–8 | 34.7–48.2 | 14 | 28 | 0.8 | 0.3, 2.0 | 0.06^F^ | B
Tangrea 1997^67^ ATBC [9242478] | 19–50 51–70^A^ | Rectal cancer (55cases; 110 controls) | 1–8 | >48.2 | 8 | 30 | 0.4 | 0.1, 1.1 | 0.06^F^ | B
Wu 2007^69^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Rectal cancer (40 cases; 80 controls) | 1–9 | 53.0, median | 11 | 30 | 1 | Reference | 0.08 | B
Wu 2007^69^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Rectal cancer (40 cases; 80 controls) | 1–9 | 73.3 | 15 | 28 | 1.74 | 0.61, 5.00 | 0.08 | B
Wu 2007^69^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Rectal cancer (40 cases; 80 controls) | 1–9 | 93.5 | 14 | 22 | 3.32 | 0.87, 12.69 | 0.08 | B
Women
Otani 2007^68^ Japan PHC [17622244] | 19–50 51–70^A^ | Rectal cancer (64 cases; 128 controls) | 1–13 | <57.2 | 20 | 24 | 1 | Reference | 0.17 | B
Otani 2007^68^ Japan PHC [17622244] | 19–50 51–70^A^ | Rectal cancer (64 cases; 128 controls) | 1–13 | 57.2–69.0 | 7 | 25 | 0.26 | 0.07, 1.0 | 0.17 | B
Otani 2007^68^ Japan PHC [17622244] | 19–50 51–70^A^ | Rectal cancer (64 cases; 128 controls) | 1–13 | 69.0–80.2 | 17 | 30 | 0.46 | 0.15, 14 | 0.17 | B
Otani 2007^68^ Japan PHC [17622244] | 19–50 51–70^A^ | Rectal cancer (64 cases; 128 controls) | 1–13 | ≥80.2 | 10 | 23 | 0.33 | 0.08, 1.3 | 0.17 | B
Feskanich 2004^70^ NHS [15342452] | 19–50 51–70^A^ | Rectal cancer (44 cases; 88 controls) | 1–11 | 44.4, median | 24 | 31 | 1 | Reference | 0.03 | B
Feskanich 2004^70^ NHS [15342452] | 19–50 51–70^A^ | Rectal cancer (44 cases; 88 controls) | 1–11 | 66.2 | 10 | 26 | 0.52 | 0.14, 1.93 | 0.03 | B
Feskanich 2004^70^ NHS [15342452] | 19–50 51–70^A^ | Rectal cancer (44 cases; 88 controls) | 1–11 | 92.4 | 10 | 31 | 0.31 | 0.08, 1.31 | 0.03 | B

* Statistically significant (P<0.05)

A Most representative life stage.

B P for trend = 0.31 when cases diagnosed within 2 years of blood collection were excluded.

C Results were not notably changed when cases diagnosed within the first year after blood collection were excluded (P for trend not reported). Subgroup analyses per age were also reported as follows: Age ≥ 60, OR = 0.35 (95% CI 0.14, 0.87) between the lowest and highest quintiles; P for trend = 0.006. Age < 60, OR = 1.36 (95% CI 0.48, 3.92) between the lowest and highest quintiles; P for trend = 0.70.

D P for trend = 0.008 when cases diagnosed within 2 years of blood collection were excluded.

E P for trend = 0.58 when cases diagnosed within 2 years of blood collection were excluded.

F P for trend = 0.04 when cases diagnosed within 2 years of blood collection were excluded.

Figure 8 Colorectal cancer risk stratified by vitamin D concentration

Figure 9 Colon cancer risk stratified by vitamin D concentration

Figure 10 Rectal cancer risk stratified by vitamin D concentration

A total of seven nested case-control studies evaluated the associations between 25(OH)D concentrations and risk of colorectal cancer67–71 or colon cancer.72, 73 The number of pairs of cases and controls in these studies ranged from 101 to 588. Another cohort study comprising 16,818 adult community volunteers from the NHANES III53 assessed the association between 25(OH)D concentrations and colorectal cancer mortality. The mean age of the subjects ranged from 44 to 66 years. Locations of the studies ranged from 20° N to 60° N. Baseline 25(OH)D concentrations ranged from 10 nmol/L to 227.5 nmol/L. No studies reported followup 25(OH)D concentrations. Time between blood drawn and the diagnosis of colorectal cancer incidence or mortality ranged from less than 1 year to 17 years. None of the studies reported power calculations. Methodological quality of five nested case-control studies67–71 were rated B and two were rated C.72, 73 Common reasons for downgrading the quality ratings included exclusion of participants without available blood samples, no verification of cancer diagnosis, and lack of adequate statistical adjustments. The cohort study53 was rated B because it was unclear whether cases were verified and there was no statistical adjustment for family history.

Findings per age and sex

The NHANES III53 analyzed data for both sexes combined. An adjusted analysis found an inverse association between 25(OH)D concentrations and the risk of colorectal cancer mortality (HR: 0.28, highest [≥80 nmol/L] compared to lowest tertile [<50 nmol/L]; P for trend = 0.02). Two studies from WCC reported colon cancer incidence for both sexes combined.72, 73 One study reported a significantly lower 25(OH)D concentrations in colon cancer cases than controls (58.9 nmol/L vs. 86.6 nmol/L; P<0.001).73 Both studies reported no significant association between 25(OH)D concentrations and colon cancer risk by trend analysis.

Three studies, from the Japan PHC, HPFS, and ATBC respectively, provided data on adult men.67–69 None of the studies found an association between 25(OH)D concentrations and colorectal cancer risk. Although all three studies provided data on colon cancer and rectal cancer as subgroup analysis, only HPFS reported a significant trend between higher 25(OH)D concentrations and lower risk of colon cancer (OR 0.46, highest [median 97.0 nmol/L] compared to lowest quartile [median 48.3 nmol/L]; P for trend = 0.005).69 The HPFS also reported a subgroup analysis on men aged 65 years or older.69 No significant association was reported between 25(OH)D concentrations and colorectal cancer risk by trend analysis.

The Japan PHC and HPFS compared 25(OH)D concentrations between colorectal cancer cases and controls.68, 69 Neither reported a significant difference. One study explored subgroup analyses. Only the rectal cancer cases had significantly lower 25(OH)D concentrations compared to the controls (55 nmol/L for cases vs. 110 nmol/L for controls; P = 0.005).68

Two nested case-control studies from the NHS and Japan PHC provided data on adult women.68, 70 The NHS reported a trend between higher 25(OH)D concentrations and lower colorectal cancer risk (OR 0.53, highest [median 99.1 nmol/L] compared to lowest quintile [median 40.2 nmol/L]; P for trend = 0.02).70 This trend remained significant in a subgroup analysis of women age 60 years or older (OR 0.35 between the highest quintiles [median 99.1 nmol/L] and lowest [median 40.2 nmol/L]; P for trend = 0.006) or in rectal cancer alone (OR 0.31, highest [median 92.4 nmol/L] compared to lowest tertile [median 44.4 nmol/L]; P for trend = 0.03).70 The WHI focused on postmenopausal women.71 A significant trend was reported between higher 25(OH)D concentrations and lower colorectal cancer risk (OR 2.53, between highest [≥58.4 nmol/L] and lowest quintiles [<31.0 nmol/L]; P for Trend = 0.02).

The Japan PHC compared 25(OH)D concentrations between cases and controls; no significant difference was reported.68

Findings per special populations

No subgroup data were available regarding the association between 25(OH)D concentrations and colorectal cancer risk in obese persons. One study exclusively included male smokers aged between 50 and 69 years,67 and reported no significant association between 25(OH)D concentrations and colorectal cancer risk by trend analysis. Another study that exclusively included white population also found no association.72 In addition, another study that focused on women who were taking hormone replacement therapy reported no significant association between 25(OH)D and colorectal cancer.70

Findings excluding early cases

Three studies performed sensitivity analyses on the association between 25(OH)D concentrations and colorectal cancer risk by excluding cases diagnosed within the first 1 to 2 years after blood draw.67, 69, 70 One study found a significant association between higher 25(OH)D concentrations and lower colon cancer risk (OR 0.3, between highest [>48.2 nmol/L] and lowest quartiles [≤24.5 nmol/L]; P for Trend = 0.04), which was not significant in main analysis.67 Otherwise, the results were not materially different from the main analysis.

Findings on 1, 25-Dihydroxyvitamin D

A total of three studies evaluated the associations between 1,25(OH)_2_D concentrations and colorectal cancer risk 67,70 or colon cancer.73 None of the studies found a significant association by trend analysis. One study reported no significant association between 1,25(OH)_2_D concentrations and rectal cancer risk.67

Findings by life stage

- 0–6 mo Not reviewed
- 7 mo–2 y Not reviewed
- 3–8 y Not reviewed
- 9–18 y Not reviewed
- 19–50 y The analysis of the NHANES III with a mean age of 44 years included participants mostly within this life stage. The study found an inverse association between 25(OH)D and colorectal cancer mortality.
- 51–70 y The seven nested case-control studies included people with a mean age ranged from 55 to 66 years. A trend between higher 25(OH)D concentrations and lower colorectal cancer risk was found in two studies of women. Out of five studies that separately assessed the risk of colon cancer and rectal cancer, only one study of men and another study of women found trends between higher 25(OH)D concentrations and lower risks of colon cancer and rectal cancer, respectively. Otherwise, no association was found between 25(OH)D concentrations and cancer risk.
- ≥71 y One RCT with a mean age of 75 included participants mostly within this life stage. The trial found no difference in colorectal cancer mortality or incidence between supplemental vitamin D and no supplements.
- Postmenopause One study and a subgroup analysis in another study focused on postmenopausal women. A trend between higher 25(OH)D concentrations and lower colorectal cancer risk was found in these two studies.
- Pregnant & lactating women Not reviewed

#### Colorectal adenoma

Synopsis

No systematic reviews have evaluated the association between 25(OH)D concentrations and the risk of colorectal adenoma. One B quality nested case-control study in women found no significant association between 25(OH)D concentrations and the risk of colorectal adenoma.

Detailed presentation

(Tables 24 & 25)

Table 24 Vitamin D and colorectal adenoma: Characteristics of observational studies

| | | | | | Confounders/Effect Modifiers Adjusted
AuthorYear Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV exposure | Lifestyle | Comments
Nested case-control
Platz 2000^74^ NHS US (various) [11045788] | - Health status; - Mean age (SD), y; - Male (%) | Any 59 (7) 0 | - Assay method; - Season blood drawn | RIA (Horris 1993) All | - Colorectal adenoma risk stratified by baseline 25(OH)D quartiles | X | X | X | X | X | X | Aspirin user: 26%; Hormone replacement therapy: 36%

Table 25 Vitamin D and colorectal adenoma: Results of observational studies

Author Year Study Name [PMID] | Life Stage | Outcome (n/N; Incidence) | Followup Duration (Time to Dx) | 25(OH)D Concentration, nmol/L | No. of Cases | No. in Category | Adjusted OR | 95% CI | P for Trend | Study Quality
Nested case-control study
Colorectal adenoma
Women
Platz 2000^74^ NHS [11045788] | 19–50 51–70^A^ ≥71 | Colorectal adenoma (326 cases; 326controls) | 5 | 16.3, median | 103 | 82 | 1 | Reference | 1.0 | B
Platz 2000^74^ NHS [11045788] | 19–50 51–70^A^ ≥71 | Colorectal adenoma (326 cases; 326controls) | 5 | 22.6 | 62 | 80 | 0.64 | 0.41, 1.00 | 1.0 | B
Platz 2000^74^ NHS [11045788] | 19–50 51–70^A^ ≥71 | Colorectal adenoma (326 cases; 326controls) | 5 | 28.3 | 61 | 82 | 0.58 | 0.36, 0.95 | 1.0 | B
Platz 2000^74^ NHS [11045788] | 19–50 51–70^A^ ≥71 | Colorectal adenoma (326 cases; 326controls) | 5 | 38.0 | 100 | 82 | 1.04 | 0.66, 1.66 | 1.0 | B
Colon adenoma
Women
Platz 2000^74^ NHS [11045788] | 19–50 51–70^A^ ≥71 | Colon adenoma (261 cases; 261 controls) | 5 | 16.3, median | 79 | 64 | 1 | Reference | 1.0 | B
Platz 2000^74^ NHS [11045788] | 19–50 51–70^A^ ≥71 | Colon adenoma (261 cases; 261 controls) | 5 | 22.6 | 55 | 64 | 0.71 | 0.43, 1.18 | 1.0 | B
Platz 2000^74^ NHS [11045788] | 19–50 51–70^A^ ≥71 | Colon adenoma (261 cases; 261 controls) | 5 | 28.3 | 51 | 69 | 0.60 | 0.35, 1.02 | 1.0 | B
Platz 2000^74^ NHS [11045788] | 19–50 51–70^A^ ≥71 | Colon adenoma (261 cases; 261 controls) | 5 | 38.0 | 76 | 64 | 1.02 | 0.60, 1.73 | 1.0 | B
Rectal adenoma
Women
Platz 2000^74^ NHS [11045788] | 19–50 51–70^A^ ≥71 | Rectal adenoma (65 cases; 65 controls) | 5 | 16.3, median | 24 | 18 | 1 | Reference | 0.9 | B
Platz 2000^74^ NHS [11045788] | 19–50 51–70^A^ ≥71 | Rectal adenoma (65 cases; 65 controls) | 5 | 22.6 | 7 | 16 | 0.38 | 0.12, 0.19
Platz 2000^74^ NHS [11045788] | 19–50 51–70^A^ ≥71 | Rectal adenoma (65 cases; 65 controls) | 5 | 28.3 | 10 | 13 | 0.34 | 0.08, 1.42
Platz 2000^74^ NHS [11045788] | 19–50 51–70^A^ ≥71 | Rectal adenoma (65 cases; 65 controls) | 5 | 38.0 | 24 | 18 | 1.59 | 0.50, 5.03

* Statistically significant (P<0.05)

A Most representative life stage

One nested case-control study within the NHS evaluated the relationship between 25(OH)D concentrations and the risk of colorectal adenoma in women.74 At 5 years, an adjusted analysis found no significant association between 25(OH)D concentrations and the incidence of colorectal adenoma by trend analysis. Subgroup analyses also found no significant association between 25(OH)D concentrations and the incidence of colon or rectal adenoma. No subgroup data were available regarding age or other special populations (e.g., obese, smokers, ethnic groups, or users of contraceptives). This study was rated B because it excluded more than 50 percent of participants of the original cohort because their blood samples were not available.

Findings by life stage

- 0–6 mo Not reviewed
- 7 mo–2 y Not reviewed
- 3–8 y Not reviewed
- 9–18 y Not reviewed
- 19–50 y A proportion of participants in the NHS was in this life stage. No unique conclusions are possible for this life stage separate from those for people 51 to 70 years.
- 51–70 y The analysis of the NHS included female participants mostly within this life stage. The study found no association between 25(OH)D and the incidence of colorectal adenoma.
- ≥ 71 y A proportion of participants in the NHS was in this life stage. No unique conclusions are possible for this life stage separate from those for people 51 to 70 years.
- Postmenopause The analysis of NHS partially included postmenopausal women. However, no unique conclusions are possible for this life stage separate from those for people 51 to 70 years.
- Pregnant & lactating women Not reviewed

#### Breast cancer

Synopsis

No qualified systematic reviews evaluated the association between vitamin D and calcium intake or serum 25(OH)D concentration and risk of breast cancer. One cohort study compared serum 25(OH)D concentrations and the risk of breast cancer-specific mortality,53 and two nested case-control studies compared 25(OH)D concentrations and the risk of breast cancer.75,76 The cohort study utilizing NHANES III data found significant decrease in breast cancer-specific mortality during 9 years of followup in those with serum concentration of 25(OH)D greater than 62 nmol/L. The Nurses’ Health Study and Prostate, Lung, Colorectal, and Ovarian (PLCO) Cancer Screening Trial, however, found no significant relationship between serum concentration of 25(OH) D and risk of breast cancer diagnosis in either pre- or postmenopausal women during 7 to 12 years of followup.75,76 All three studies were rated B quality.

Detailed presentation

(Tables 26 & 27)

Table 26 Vitamin D and breast cancer: Characteristics of observational studies

Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV exposure | Lifestyle | Comments
Cohort
Freedman 2007^53^ NHANES III US (38° N) [17971526] | - Health status; - Mean age (range/SD), y | Non-institutionalized 44 (ND) | Assay methodSeason blood drawn | RIA All year | Breast cancer risks: Quintile 1 vs. Quintile 2 | X | X | X | | X | X
Nested Case-Control
Bertone-Johnson 2005^75^ NHS US (38° N) [16103450] | - Health status; - Mean age (range/SD), y | No Cancer 57 (7.0) | Assay methodSeason blood drawn | RIA All year | Breast cancer risks: Quintile 1 vs. Quintile 2, 3, 4, 5 | X | X | X | X | | X
Freedman 2008^76^ PLCO Trial US (38° N) [18381472] | - Health status; - Mean age (range/SD), y | No Cancer 67 (ND) | Assay method Seasonblood drawn | RIA Dec–Sep | Breast cancer risks: Quintile 1 vs. Quintile 2, 3, 4, 5 | X | X | X | X | | X

The NHANES III study followed 16,818 adults with a mean age of 44 years with a background calcium intake on average of about 812 mg/day (from diet and supplements). 53 The study included 71 percent non-Hispanic white, 14 percent non-Hispanic black, 6 percent Mexican American, and 9 percent from other races. During 9 years of followup, women with serum concentration of 25(OH) D greater than 62 nmol/L had a hazard ratio of 0.28 for breast cancer-specific mortality compared to those with 62 nmol/L or lower (95 percent CI 0.08–0.93). The breast cancer-specific mortality was one of many cancer-specific mortality outcomes reported in this study.

Two nested case-control studies of women with a mean age of 57 years and 67 years, respectively, found no relationship between serum 25(OH)D concentrations and risk of breast cancer.75,76 However, in the second study, when compared with the lowest quintile, quintiles 3 to 5 were associated with nonsignificantly elevated risks. In multivariable adjusted analyses, the risk associated with 25(OH)D levels below 15 ng/mL compared with higher levels was 0.81 (95 percent CI 0.59, 1.12).76

Findings by age and sex

In the one nested case-control study (methodological quality B) including both premenopausal and postmenopausal women, no relationship was found between vitamin D levels and risk of breast cancer. However, in this study, there was a statistically significant trend towards decreased risk of breast cancer among women older than 60 years of age with serum concentration of 25(OH)D greater than 62 nmol/L.

Findings by life stage

- 0–6 mo Not applicable
- 7 mo–2 y Not applicable
- 3–8 y Not applicable
- 9–18 y Not applicable
- 19–50 y A followup study of NHANES III including women with a mean age of 44 years found a decreased mortality (hazard ratio 0.28) due to breast cancer among those with serum concentration of 25(OH)D greater than 62 nmol/L.
- 51–70 y Two nested case-control studies of women with a mean age of 57 years and 67 years, respectively, found no relationship between vitamin D levels and risk of breast cancer. However, in one of these studies, there was a statistically significant trend towards decreased risk of breast cancer among women older than 60 years of age with serum concentration of 25(OH)D greater than 62 nmol/L.
- ≥71 y Not reviewed
- Postmenopause Not reviewed
- Pregnant & lactating women Not reviewed

Table 27 Vitamin D and breast cancer: Results of observational studies

Author Year Study Name [PMID] | Life Stage | Outcome (n/N; Incidence) | Followup Duration (Time to Dx) | Vit D Measure | Concentration, nmol/L | No. of Cases | No. in Category | Adjusted RR | 95% CI | P for Trend | Study Quality
Cohort
Freedman 2007^53^ NHANES III [17971526] | All Adults | Breast cancer mortality (28/ND)^A^ | 105 mo | 25(OH)D | <63 | 20 | ND | 1 | Reference | NS | B
Freedman 2007^53^ NHANES III [17971526] | All Adults | Breast cancer mortality (28/ND)^A^ | 105 mo | 25(OH)D | ≥63 | 8 | ND | HR 0.28 | 0.08, 0.93^*^ | NS | B
Nested Case-Control
Bertone-Johnson 2005^75^ NHS [16103450] | Pre- and Post- menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | ≤50 (1^st^ batch) ≤70 (2^nd^ batch) ≤45 (3^rd^ batch) | 159 | 297 | 1 | Reference | nd | B
Bertone-Johnson 2005^75^ NHS [16103450] | Pre- and Post- menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | 51–70 72–85 47 to 60 | 149 | 278 | 0.95 | 0.66, 1.36 | nd | B
Bertone-Johnson 2005^75^ NHS [16103450] | Pre- and Post- menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | 72–82 87–97 62–72 | 125 | 266 | 0.74 | 0.51, 1.06 | nd | B
Bertone-Johnson 2005^75^ NHS [16103450] | Pre- and Post- menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | 85–97 100–117 75–90 | 144 | 296 | 0.80 | 0.58, 1.11 | nd | B
Bertone-Johnson 2005^75^ NHS [16103450] | Pre- and Post- menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | ≥100 ≥120 ≥92 | 124 | 265 | 0.73 | 0.49, 1.07 | nd | B
Bertone-Johnson 2005^75^ NHS [16103450] | Pre- and Post- menopausal | Breast cancer <60 y (701/1425) | | | | 97 | 191 | 1 | Reference | NS | B
Bertone-Johnson 2005^75^ NHS [16103450] | Pre- and Post- menopausal | Breast cancer <60 y (701/1425) | | | | 84 | 170 | 0.96 | 0.62, 1.49 | NS | B
Bertone-Johnson 2005^75^ NHS [16103450] | Pre- and Post- menopausal | Breast cancer <60 y (701/1425) | | | | 77 | 164 | 0.80 | 0.51, 1.26 | NS | B
Bertone-Johnson 2005^75^ NHS [16103450] | Pre- and Post- menopausal | Breast cancer <60 y (701/1425) | | | | 90 | 192 | 0.85 | 0.55, 1.32 | NS | B
Bertone-Johnson 2005^75^ NHS [16103450] | Pre- and Post- menopausal | Breast cancer <60 y (701/1425) | | | | 70 | 146 | 0.92 | 0.57, 1.48 | NS | B
Bertone-Johnson 2005^75^ NHS [16103450] | Pre- and Post- menopausal | Breast cancer ≥60 y (701/1425) | | | | 62 | 109 | 1 | Reference | 0.03 | B
Bertone-Johnson 2005^75^ NHS [16103450] | Pre- and Post- menopausal | Breast cancer ≥60 y (701/1425) | | | | 65 | 114 | 1.07 | 0.60, 1.92 | 0.03 | B
Bertone-Johnson 2005^75^ NHS [16103450] | Pre- and Post- menopausal | Breast cancer ≥60 y (701/1425) | | | | 48 | 105 | 0.64 | 0.35, 1.16 | 0.03 | B
Bertone-Johnson 2005^75^ NHS [16103450] | Pre- and Post- menopausal | Breast cancer ≥60 y (701/1425) | | | | 54 | 99 | 0.68 | 0.38, 1.24 | 0.03 | B
Bertone-Johnson 2005^75^ NHS [16103450] | Pre- and Post- menopausal | Breast cancer ≥60 y (701/1425) | | | | 54 | 125 | 0.57 | 0.31, 1.04 | 0.03 | B
Freedman 2008^76^ PLCO Cancer Screening Trial [18381472] | Pre- and Post- menopausal | Breast cancer (1005/2010) | 12 y | 25(OH)D | <46 | 172 | 2010 | 1 | Reference | NS | B
Freedman 2008^76^ PLCO Cancer Screening Trial [18381472] | Pre- and Post- menopausal | Breast cancer (1005/2010) | 12 y | 25(OH)D | 46–58 | 188 | 2010 | 1.02 | 0.75, 1.41 | NS | B
Freedman 2008^76^ PLCO Cancer Screening Trial [18381472] | Pre- and Post- menopausal | Breast cancer (1005/2010) | 12 y | 25(OH)D | 59–71 | 244 | 2010 | 1.36 | 0.99, 1.87 | NS | B
Freedman 2008^76^ PLCO Cancer Screening Trial [18381472] | Pre- and Post- menopausal | Breast cancer (1005/2010) | 12 y | 25(OH)D | 72–83 | 205 | 2010 | 1.13 | 0.82, 1.55 | NS | B
Freedman 2008^76^ PLCO Cancer Screening Trial [18381472] | Pre- and Post- menopausal | Breast cancer (1005/2010) | 12 y | 25(OH)D | ≥84 | 196 | 2010 | 1.04 | 0.75, 1.45 | NS | B

* Statistically significant (P<0.05)

A Total number of women not reported

#### Pancreatic cancer

Synopsis

No qualified systematic reviews evaluated associations between serum vitamin D concentrations and the incidence of pancreatic cancer. Two nested case-control studies, rated A in methodological quality, evaluated the association between serum 25(OH) concentration and the risk of developing pancreatic cancer in two different populations. One study found that older adult male smokers living in Finland with higher baseline serum 25(OH)D concentration had an increased risk of exocrine pancreatic cancer compared with those with lower concentration (>65.5 vs. <32 nmol/L; OR=2.92; P for trend=0.001). The other study found that baseline 25(OH)D concentrations were not associated with the risk of overall pancreatic cancer (>82.3 vs. <45.9 nmol/L; OR=1.45; P for trend=0.49) among older adults living in the United States. However, there was an increased risk of pancreatic cancer among the study participants with higher compared to lower 25(OH)D concentrations (>78.4 vs. <49.3 nmol/L; OR=4.03) only in those living in low residential UVB exposure areas but not among those living in moderate or high residential UVB exposure areas.

Detailed presentation

(Tables 28 & 29)

Table 28 Vitamin D and pancreatic cancer: Characteristics of observational studies

Author Year Trial/Cohort Country (Latitude) [PMID] | Population | | 25(OH)D | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Trial/Cohort Country (Latitude) [PMID] | Population | | 25(OH)D | | Comparisons | Nutrients | Demographic | Anthrop | Medical | UV exposure | Life styles | Comments
Stolzenberg-Solomon 2006^77^ ATBC Finland (60°N) [17047087] | Health status Mean age (range/SD), y Male (%) | All smokers 58 100 | AssaySeason blood drawn | RIA (DiaSorin) nd; but result adjusted for this variable | Exocrine pancreatic risk stratified by baseline 25(OH)D quintiles | X | X | | | X | X
Stolzenberg- Solomon 2009^78^ PLCO US (various) [19208842] | Health status Mean age (range), y Male (%) | DM: 10.5% 66 (55–74) 65.2 | AssaySeason blood drawn | RIA (Heartland Assays lab) All seasons | Pancreatic risk stratified by baseline 25(OH)D quintiles Pancreatic risk stratified by residential sun exposure levels and baseline 25(OH)D quartiles | | X | X | | X | X

Table 29 Vitamin D and pancreatic cancer: Results of observational studies

Author Year Study Name PMID | Life Stage, y | Outcome (no. of cases; no. of control) | Time to diagnosis, y | 25(OH)D concentration, nmol/L | No. of cases | No. of control | Adjusted OR | 95% CI | P for trend | Study Quality
Stolzenberg-Solomon 2006^77^ ATBC Finland (60°N) [17047087] | 51–70, male only | Exocrine pancreatic cancer (200; 400) | 11.8 (median) | <32 | 27 | 80 | 1 | Reference | 0.001 | A
Stolzenberg-Solomon 2006^77^ ATBC Finland (60°N) [17047087] | 51–70, male only | Exocrine pancreatic cancer (200; 400) | 11.8 (median) | 32–41.1 | 34 | 80 | 1.30 | 0.70, 2.40 | 0.001 | A
Stolzenberg-Solomon 2006^77^ ATBC Finland (60°N) [17047087] | 51–70, male only | Exocrine pancreatic cancer (200; 400) | 11.8 (median) | 41.1–51.1 | 47 | 80 | 2.12 | 1.15, 3.90^*^ | 0.001 | A
Stolzenberg-Solomon 2006^77^ ATBC Finland (60°N) [17047087] | 51–70, male only | Exocrine pancreatic cancer (200; 400) | 11.8 (median) | 51.1–65.5 | 35 | 81 | 1.50 | 0.81, 2.76 | 0.001 | A
Stolzenberg-Solomon 2006^77^ ATBC Finland (60°N) [17047087] | 51–70, male only | Exocrine pancreatic cancer (200; 400) | 11.8 (median) | >65.5 | 57 | 79 | 2.92 | 1.56, 5.48^*^ | 0.001 | A
Stolzenberg-Solomon 2009^78^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer (184; 368) | 5.4 (median), up to 11 y | ≤45.9 | 44 | 74 | 1 | Reference | 0.49 | A
Stolzenberg-Solomon 2009^78^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer (184; 368) | 5.4 (median), up to 11 y | >45.9 to ≤60.3 | 40 | 74 | 0.97 | 0.47, 1.98 | 0.49 | A
Stolzenberg-Solomon 2009^78^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer (184; 368) | 5.4 (median), up to 11 y | >60.3 to ≤69.5 | 27 | 73 | 0.86 | 0.40, 1.84 | 0.49 | A
Stolzenberg-Solomon 2009^78^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer (184; 368) | 5.4 (median), up to 11 y | >69.5 to ≤82.3 | 31 | 74 | 0.84 | 0.39, 1.80 | 0.49 | A
Stolzenberg-Solomon 2009^78^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer (184; 368) | 5.4 (median), up to 11 y | >82.3 | 42 | 73 | 1.45 | 0.66, 3.15 | 0.49 | A
Stolzenberg-Solomon 2009^78^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer: Low residential sun exposure area (91; 167) Pancreatic cancer: Moderate residential sun exposure area (91; 167) | nd nd | <49.3 | 22 | 44 | 1 | Reference | P for interaction between low and moderate/high residential sun exposure = 0.015
Stolzenberg-Solomon 2009^78^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer: Low residential sun exposure area (91; 167) Pancreatic cancer: Moderate residential sun exposure area (91; 167) | nd nd | >49.3 to <65.2 | 22 | 42 | 2.52 | 0.92, 6.90 | P for interaction between low and moderate/high residential sun exposure = 0.015
Stolzenberg-Solomon 2009^78^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer: Low residential sun exposure area (91; 167) Pancreatic cancer: Moderate residential sun exposure area (91; 167) | nd nd | >65.2 to <78.4 | 21 | 43 | 2.33 | 0.83, 6.48 | P for interaction between low and moderate/high residential sun exposure = 0.015
Stolzenberg-Solomon 2009^78^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer: Low residential sun exposure area (91; 167) Pancreatic cancer: Moderate residential sun exposure area (91; 167) | nd nd | >78.4 | 26 | 38 | 4.03 | 1.38, 11.79^*^ | P for interaction between low and moderate/high residential sun exposure = 0.015
Stolzenberg-Solomon 2009^78^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer: Low residential sun exposure area (91; 167) Pancreatic cancer: Moderate residential sun exposure area (91; 167) | nd nd | <49.3 | 33 | 48 | 1.97 | 0.80, 4.82 | P for interaction between low and moderate/high residential sun exposure = 0.015
Stolzenberg-Solomon 2009^78^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer: Low residential sun exposure area (91; 167) Pancreatic cancer: Moderate residential sun exposure area (91; 167) | nd nd | >49.3 to <65.2 | 15 | 50 | 0.66 | 0.22, 2.01 | P for interaction between low and moderate/high residential sun exposure = 0.015
Stolzenberg-Solomon 2009^78^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer: Low residential sun exposure area (91; 167) Pancreatic cancer: Moderate residential sun exposure area (91; 167) | nd nd | >65.2 to <78.4 | 18 | 49 | 0.91 | 0.31, 2.71 | P for interaction between low and moderate/high residential sun exposure = 0.015
Stolzenberg-Solomon 2009^78^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer: Low residential sun exposure area (91; 167) Pancreatic cancer: Moderate residential sun exposure area (91; 167) | nd nd | >78.4 | 24 | 54 | 1.45 | 0.53, 3.96 | P for interaction between low and moderate/high residential sun exposure = 0.015

* Statistically significant (P<0.05)

51–74 years

One nested case-control study based on the Alpha-Tocopherol, Beta-Carotene Cancer Prevention Study (ATBC) in older adult male smokers aged 54 to 62 years in Finland identified 200 cases of incident exocrine pancreatic cancer.77 These cases were matched to 400 controls. Baseline serum 25(OH)D concentration was stratified into quintiles. The odds ratio for exocrine pancreatic cancer was 2.92 (95 percent CI 1.56, 5.48) comparing 5^th^ quintile (>65.5 nmol/L) to 1^st^ quintile (<32 nmol/L). The result was adjusted for age, month of blood drawn, years smoked, number of cigarettes smoked per day, reporting to have quit smoking more than three consecutive visits (>1 y) during the trial (1985–1993), occupational physical activity, education, and serum retinol. The study authors excluded islet cell carcinomas from analysis because the etiology for their pathogenesis might be different from that of exocrine tumors.

Another nested case-control study based on the Prostate, Lung, Colorectal, and Ovarian Screening (PLCO) trial in older men and women aged 55 to 74 years in the United States identified 184 cases of incident pancreatic cancer.78 These cases were matched to 368 controls. Baseline serum 25(OH)D concentration was stratified into quintiles. The odds ratio for exocrine pancreatic cancer was 1.45 (95 percent CI 0.66, 3.15) comparing 5th quintile (>82.3 nmol/L) to 1st quintile (<45.9 nmol/L). The result was adjusted for age, race, sex, date of blood draw based on 2-month blocks, BMI and smoking. The association was not significantly modified by season of blood collection (P for interaction > 0.14); but estimated residential annual solar UVB exposure significantly modified the 25(OH)D concentration and pancreatic cancer association (P for interaction = 0.015). In the joint effects models, among subjects with low estimated annual UVB residential exposure, higher compared with lower 25(OH)D concentrations were associated with increased risk of pancreatic cancer (compared with the lowest quartile, the ORs for each respective quartile were 2.52, 2.33, and 4.03; 95 percent CI 1.38, 11.79), whereas among subjects with moderate to high residential UVB exposure, 25(OH)D concentrations were not associated with pancreatic cancer. There was no significant interaction of 25(OH)D concentration and pancreatic cancer by smoker status, sex, physical activity, or total vitamin A intake.

Findings by life stage

- 0–6 mo not reviewed
- 7 mo–2 y not reviewed
- 3–8 y not reviewed
- 9–18 y not reviewed
- 19–50 y No study specifically targeted this age group.
- 51–70 y One nested case-control study found that male smokers living in Finland with higher baseline serum 25(OH)D concentration had an increased risk of pancreatic cancer compared with those with lower concentration (5^th^ vs. 1^st^ quintile, >65.5 vs. <32 nmol/L: OR 2.92, 95 percent CI 1.56, 5.48, P for trend = 0.001). Another study found that baseline 25(OH)D concentrations were not associated with overall risk of pancreatic cancer among older adults living in the United States (5^th^ vs. 1^st^ quintile, >82.3 vs. <45.9 nmol/L: OR 1.45, 95 percent CI 0.66, 3.15; P for trend=0.49). However, there was an increased risk of pancreatic cancer among the study participants living in low residential UVB exposure areas (4^th^ vs. 1^st^ quartile >78.4 vs. <49.3 nmol/L: OR=4.03; 95 percent CI 1.38, 11.79).
- ≥71 y No study specifically targeted this age group.
- Postmenopause not reviewed
- Pregnant & lactating women not reviewed

### Vitamin D and Immunologic Outcomes

We reviewed primary studies that evaluated relationships between vitamin D and any immune function related outcomes.

Synopsis

Analyses using NHANES III data (general adult populations living in the US) showed no significant association between baseline 25(OH)D concentrations and infectious disease mortality.

One cohort study from UK suggested a relationship between maternal 25(OH)D concentration and the risk of eczema in their children, but the analysis did not control for important potential confounders, and the 25(OH)D concentrations in children were not measured.

Detailed presentation

(Tables 30 & 31)

Table 30 Vitamin D (mother) and immunologic outcomes (offspring): Characteristics of cohort studies

Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV exposure | Lifestyle | Comments
Melamed 2008^47^ NHANES III US (various) [18695076] | - Health status; - Mean age (range), y; - Male (%) | DM 7.4%, history of CVD 7.9%, HTN 25% 45 (≥20) 46 | Assay methodSeason blood drawn | RIA (DiaSorin) All | Infectious disease mortality stratified by baseline 25(OH)D quartiles | X | X | X | X | X | X
Gale 2008^42^ PAHSG UK (50°N) [17311057] | - Health status; - Mean age (range/SD), y; - Male (%) | singleton pregnancy y < 17 wk 26.3 0 | Assay methodSeason blood drawn | RIA nd | Length and weight in offspring stratified by mother’s 25(OH)D | | X | | | X | | White only

Table 31 Vitamin D (mother) and immunologic outcomes (offspring): Results of cohort studies

Author Year Study Name [PMID] | Life Stage | Outcome (n/N; Incidence) | Followup Duration (Time to Dx) | Vit D Measure | Concentration, nmol/L | No. of Cases | No. in Category | Adjusted OR | 95% CI | P for Trend | Study Quality
Melamed 2008^47^ NHANES III US (various) [18695076] | Adults, both sexes | Infectious disease mortality (N=13,331) | Median 8.7 (IRQ 7.1–10.2) y | 25(OH)D | <44 | nd | 13331 (Total) | 0.84 | 0.38, 1.86 | nd | C
Melamed 2008^47^ NHANES III US (various) [18695076] | Adults, both sexes | Infectious disease mortality (N=13,331) | Median 8.7 (IRQ 7.1–10.2) y | 25(OH)D | 44–60 | nd | nd | 0.87 | 0.43, 1.74 | nd | C
Melamed 2008^47^ NHANES III US (various) [18695076] | Adults, both sexes | Infectious disease mortality (N=13,331) | Median 8.7 (IRQ 7.1–10.2) y | 25(OH)D | 61–80 | nd | nd | 1.01 | 0.53, 1.93 | nd | C
Melamed 2008^47^ NHANES III US (various) [18695076] | Adults, both sexes | Infectious disease mortality (N=13,331) | Median 8.7 (IRQ 7.1–10.2) y | 25(OH)D | >80 | nd | nd | 1 | Reference | nd | C
Gale 2008^42^ PAHSG UK (54°N) [17311057] | Pregnant women; infant at 9 mo | Atopic eczema at 9 mo (48/440; 0.11) | 9 mo | Maternal 25(OH)D at late pregnancy | <30 (Quartile) | 9 | 440 (total) | 1 | Reference | nd | C
Gale 2008^42^ PAHSG UK (54°N) [17311057] | Pregnant women; infant at 9 mo | Atopic eczema at 9 mo (48/440; 0.11) | 9 mo | Maternal 25(OH)D at late pregnancy | 30–50 | 10 | | 1.11^A^ | 0.43, 2.84 | nd | C
Gale 2008^42^ PAHSG UK (54°N) [17311057] | Pregnant women; infant at 9 mo | Atopic eczema at 9 mo (48/440; 0.11) | 9 mo | Maternal 25(OH)D at late pregnancy | 50–75 | 15 | | 1.75^A^ | 0.73, 4.17 | nd | C
Gale 2008^42^ PAHSG UK (54°N) [17311057] | Pregnant women; infant at 9 mo | Atopic eczema at 9 mo (48/440; 0.11) | 9 mo | Maternal 25(OH)D at late pregnancy | >75 | 14 | | 1.62^A^ | 0.67, 3.89 | nd | C

A Crude OR

One study analyzed NHANES III data and showed no association between baseline 25(OH)D concentrations and infectious disease.47 NHANES III cohort represents general adult populations living in the United States. This study was rated quality C.

One cohort study from UK analyzed the serum 25(OH)D concentration in 440 white women in late pregnancy (~33 wk) and found their infants’ risk of eczema at age 9 months was higher in those mothers in the top quartile of the distribution of serum 25(OH)D (>50 nmol/L) compared with those at the bottom quartile (<30 nmol/L), although the results were not statistically significant.42 However, this analysis did not control for important potential confounders, and the 25(OH)D concentrations in children were not measured. This study was rated quality C.

Findings by life stage

- 0–6 mo No data
- 7 mo–2y No data
- 3–8 y No data
- 9–18 y No data
- 19–50 y NHANES III data include people in this life stage. Analyses using NHANES III data (general adult populations living in the US) showed no significant association between baseline 25(OH)D concentrations and infectious disease mortality.
- 51–70 y NHANES III data also include people in this life stage.
- ≥71 y NHANES III data also include people in this life stage
- Postmenopause No data
- Pregnant & lactating women One cohort study from UK analyzed the serum 25(OH)D concentration in white women in late pregnancy (~33 wk) and showed a relationship between maternal 25(OH)D concentration and the risk of eczema in their children. However, this analysis did not control for important confounders, and the 25(OH)D concentrations in children were not measured.

### Vitamin D and Pregnancy-related Outcomes

#### Preeclampsia

Synopsis

A single nested case-control study found an association between low 25(OH)D concentration (<37.5 nmol/L) early in pregnancy and preeclampsia. The study was rated B for methodological quality.

Detailed presentation

(Tables 32 & 33)

Table 32 Vitamin D and preeclampsia: Characteristics of nested case-control studies

Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Confounders/Effect Modifiers Adjusted
Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV exposure | Lifestyle
Bodnar 2007^79^ PEPPS^A^ US (41°N) [17535985] | - Health status; - Age range, y; - Male (%) | Healthy 20–29 0 | Assay methodSeason blood drawn | ELISA ND | Comparison of mean 25(OH)D levels in cases and controls | | x | x

A Pregnancy Exposures and Preeclampsia Prevention Study

Table 33 Vitamin D and preeclampsia: Results of nested case-control studies

Author Year Study Name Location (Latitude) [PMID] | Life Stage | Outcome (n/N; Incidence) | Followup Duration (Time to Dx) | Vit D Measure | Concentration, nmol/L | No. of Cases | No. in Category | Adjusted OR | 95% CI | Study Quality
Bodnar 2007^79,A^ PEPPS^B^ US (41°N) [17535985] | Pregnancy | Preeclampsia(55/1198; 4%)^C^ | ND | 25(OH)D^D^ | <37.5 (vs. >37.5) | 49 | 265 | 5.0 | 1.7, 14.1 | B

A This is a nested case-control study

B Pregnancy Exposures and Preeclampsia Prevention Study

C Incidence obtained from the “parent” cohort study in which this case control study is nested.

D Early in pregnancy, approximately 30 wk before outcome assessment

A nested case-control study evaluated the association between 25(OH)D concentration and risk of preeclampsia.79 The study found an association between 25(OH)D concentrations less than 37.5 nmol/L (measured approximately 30 wk before outcome assessment) and increased risk of preeclampsia. The study was rated B for methodological quality.

Findings by life stage

- 0–6 mo No data
- 7 mo–2 y Not applicable
- 3–8 y Not applicable
- 9–18 y Not applicable
- 19–50 y See pregnant and lactating women.
- 51–70 y Not applicable
- ≥71 y Not applicable
- Postmenopause Not applicable
- Pregnant & lactating women A single nested case-control study found an association between low 25(OH)D concentration (<37.5 nmol/L) early in pregnancy and preeclampsia.

#### Other outcomes

Synopsis

We did not identify any eligible studies on the relationship of vitamin D with or without calcium and high blood pressure, preterm birth, or small infant for gestational age.

### Vitamin D and Clinical Outcomes of Bone Health

For bone health outcomes (e.g., bone mineral density, fracture, fall or muscle strength), we relied on a recent comprehensive systematic review (Effectiveness and Safety of Vitamin D in Relation to Bone Health) performed by the Ottawa EPC (Table 28).6 Because the Ottawa’s EPC report did not report separate analyses for the effect of vitamin D supplementation alone, the results for the effect of vitamin D alone or in combination with calcium supplementation were presented in the “Combined Vitamin D and Calcium” section. The Ottawa EPC report also did not report separate analyses by study designs (i.e., RCTs, prospective cohorts, before and after study, and case-control studies), although the report primarily included RCTs.

The Ottawa EPC report was updated with literature published between January 2006 and September 2008, selected according to our eligibility criteria. Only RCTs qualified for inclusion.

#### Rickets

Synopsis

The Ottawa EPC report concluded that there is fair evidence for an association between low serum 25(OH)D concentrations and confirmed rickets, regardless of the types of assay measures of 25(OH)D concentrations (RIA, CPBA, HPLC). According to the report, there is inconsistent evidence to determine whether there is a threshold concentration of serum 25(OH)D above which rickets do not occur.

Our updated search did not identify new RCTs examining the effect of vitamin D supplementation on rickets.

Detailed presentation

(Table 34)

Table 34 Summary of systematic review of the effect of vitamin D on bone health

Author Year [PMID] | Cranney 2007^6^ [18088161]
Design | Systematic review of RCTs and observational studies
Population | - Include all ages; - Exclude secondary causes of osteoporosis (e.g., glucocorticoid-induced, renal or liver disease); - Exclude studies on the treatment of vitamin D-dependent rickets (to minimize clinical heterogeneity as treatments is often nondietary sources of vitamin D)
Intervention (Exposure) and Comparator | Intervention (Exposure):; - Include vitamin D_2_ or D_3_ with or without calcium.; - Exclude vitamin D preparations, calcitriol, α-calcidol (because they are not nutritional supplements, and have different safety profile); Comparator:; - No vitamin D or lower doses/levels of vitamin D
Results | See text for summary results for the following outcomes in both vitamin D and combined vitamin D and calcium sections of the report:; - Rickets; - Fractures, falls, or performance measures; - Bone mineral density or bone mineral contents; - How does dietary intake of vitamin D from fortified foods and vitamin D supplementation affect serum 25(OH)D Concentrations; - Adverse events
Comments | Case-control studies were included but always summarized separately from cohort studies and RCTs. Meta-analyses were performed to pool results from RCTs only.
AMSTAR
A priori design? | Yes | Study quality assessment performed? | Yes
Two independent reviewers? | Yes | Study quality appropriatelpy used in analysis? | Yes
Comprehensive literature search? | Yes | Appropriate statistical synthesis? | Yes
All publication types and languages included? | No | Publication bias assessed? | No
Included and excluded studies listed? | Yes | Conflicts of interest stated? | Yes
Study characteristics provided? | Yes

Ottawa EPC Report: Rickets - infants (0 through 12 months) and young children (1 through 5 years)

Overall, there is fair evidence for an association between low serum 25(OH)D concentrations and confirmed rickets, regardless of the types of assay measures of 25(OH)D concentrations (RIA, CPBA, HPLC). There is inconsistent evidence to determine whether there is a threshold concentration of serum 25(OH)D above which rickets do not occur.

Six studies (one RCT, three before-after and two case-control studies) reported mean or median serum 25(OH)D concentrations < 30 nmol/L in children with rickets whereas the other studies reports the mean or median 25(OH)D concentrations were above 30 nmol/L (and up to 50 nmol/L). In seven of eight case-control studies, serum 25(OH)D concentrations were lower in the children with rickets compared with controls.

Findings by life stage

- 0–6 mo The Ottawa EPC report included infants and young children and concluded that there is fair evidence for an association between low serum 25(OH)D concentrations and confirmed rickets, regardless of the types of assay measures of 25(OH)D concentrations (RIA, CPBA, HPLC). There were no new data since the Ottawa EPC report.
- 7 mo–2 y The Ottawa EPC report included infants and young children. There were no new data since the Ottawa EPC report.
- 3–8 y The Ottawa EPC report included young children. There were no new data since the Ottawa EPC report.
- 9–18 y Not reviewed
- 19–50 y Not reviewed
- 51–70 y Not reviewed
- ≥71 y Not reviewed
- Postmenopause Not reviewed
- Pregnant & lactating women Not reviewed

#### Fractures, falls, or performance measures

Synopsis

Overall, the Ottawa EPC report concluded that the associations between serum 25(OH)D concentrations and the risk of fractures, falls, and performance measures among postmenopausal women or elderly men are inconsistent.6

Findings from three additional RCTs (published after the Ottawa EPC report)80–82 also did not show significant effects of either vitamin D_2_ or D_3_ supplementation (daily doses ranged from 400 IU to 822 IU) in reducing the risk of total fractures or falls in elderly populations (≥71 years old).

Detailed presentation

(Tables 35 & 36)

Table 35 Vitamin D and bone health: Characteristics of RCTs published after the Ottawa EPC report

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Lyons 2007^82^ South Wales, UK (52°N) [17473911] | - Health status; - Mean age (range), y; - Male (%) | Living in care facilities including some elderly with mobility, cognitive, visual, hearing or communication impairments 84 (62–107) 23.7 | nd | Vit D_2_ 100,000 IU 4-monthly vs. placebo | 80% (percentage of occasions observed to take tablets)
Burleigh 2007^81^ Scotland (55° 57’N) [17656420] | - Health status; - Mean age(SD), y; - Male (%) | Inpatient with high levels of comorbidity, mortality and polypharmacy 83 (7.6) 40 | 25(OH)D: 22.0 nmol/L | Vit D_3_ 800 IU/d + Ca carbonate1200 mg/d vs. Ca carbonate 1200 mg | Ca group=87%, Vit D+Ca group=89% (total study drug taken/total study drug prescribed, as recorded in drug prescription charts)
Bunout 2006^80^ Chile (32°S) [16797903] | - Health status; - Mean age (SD), y; - Male (%) | Healthy 76 (4) 11.6 | 25(OH)D: ≤40 nmol/L | Ca 800 mg/d vs. Ca 800 mg/d + Vit D 400 IU/d (with and without exercise training) | 92% (tablet counting)

Table 36 Vitamin D and bone health: Results of RCTs published after the Ottawa EPC report

Author Year Study Name [PMID] | Life Stage | Outcome | 1°/2° | Mean Followup | Interventions, Daily Dose | n Event | N Total | Outcome Metric (Comparison) | Result | 95% CI | P Btw | Study Quality
Lyons 2007^82^ [17473911] | ≥71 both sexes | First fracture | 1° | Median time to first fracture = 387 (IQR: 220–582) d in Vit D_2_ group; 367 (IQR:139–618) d in placebo group | Vit D_2_ ~822 IU^A^ | 205 | 1670 | HR Vit D/placebo | 0.95 | 0.79, 1.15 | NS | C
Lyons 2007^82^ [17473911] | ≥71 both sexes | First fracture | 1° | Median time to first fracture = 387 (IQR: 220–582) d in Vit D_2_ group; 367 (IQR:139–618) d in placebo group | Placebo | 218 | 1673 | | | | | C
Burleigh 2007^81^ [17656420] | ≥71 both sexes | Fall | 1° | Median 1 (IQR 15–71 d) | Vit D_3_ 800 IU + Ca carbonate 1200 mg | 36 | 100 | RR (Vit D+Ca)/Ca | 0.82 | 0.59, 1.16 | NS | C
Burleigh 2007^81^ [17656420] | ≥71 both sexes | Fall | 1° | Median 1 (IQR 15–71 d) | Ca carbonate 1200 mg | 45 | 103 | | | | | C
Burleigh 2007^81^ [17656420] | ≥71 both sexes | Fracture | 1° | Median 1 (IQR 15–71 d) | Vit D_3_ 800 IU + Ca carbonate 1200 mg | 1 | 100 | nd | nd | | NS | C
Burleigh 2007^81^ [17656420] | ≥71 both sexes | Fracture | 1° | Median 1 (IQR 15–71 d) | Ca carbonate 1200 mg | 3 | 103 | | | | | C
Bunout 2006^80^ [16797903] | ≥71 both sexes | Fall | 2° | 9 mo | Ca 800 mg | 13^B^ | 24 | Fall free survival curve | nd | | NS | C
Bunout 2006^80^ [16797903] | ≥71 both sexes | Fall | 2° | 9 mo | Ca 800 mg + exercise training | 6^B^ | 22 | | | | | C
Bunout 2006^80^ [16797903] | ≥71 both sexes | Fall | 2° | 9 mo | Vit D 400 IU + Ca 800 mg | 9B | 24 | | | | | C
Bunout 2006^80^ [16797903] | ≥71 both sexes | Fall | 2° | 9 mo | Vit D 400 IU + Ca 800 mg + Exercise training | 8B | 22 | | | | | C

A Daily dose was calculated from the intermittent doses that were used in the study (i.e., 100,000 IU tablets every 4 months)

B Estimated from figure

Ottawa EPC Report: Fractures - Postmenopausal women or elderly men

Overall, there is inconsistent evidence for an association between serum 25(OH)D concentrations and the risk of fractures. Fifteen studies (three prospective cohorts and twelve case-controls) reported on the association between serum 25(OH)D concentrations and fracture rates. One of three cohorts reported an inverse association between serum 25(OH)D concentrations and fracture rates, and nine of twelve case-control studies found significantly lower 25(OH)D concentrations in cases versus controls. Differences in results may be attributed to whether all relevant confounders were controlled for and differences in baseline serum 25(OH)D concentrations. Other factors may also contribute to the heterogeneity, such as diagnosis of fractures.

Ottawa EPC Report: Falls - Postmenopausal women or elderly men

Overall, there is fair evidence of an association between lower serum 25(OH)D concentrations and an increased risk of falls in institutionalized elderly. One study suggested a serum 25(OH)D concentration below 39 nmol/L was associated with an increased risk of falls.

Five studies (one RCT, three cohorts and one case-control) evaluated the association between serum 25(OH)D concentrations and risk of falls. One RCT, two of the three cohorts and one case-control study reported an inverse association between serum 25(OH)D concentrations and a risk of falls. In one cohort with a low percentage of vitamin D deficient participants, the association did not persist after adjustment for age and illness severity. In another cohort with an undetermined proportion of vitamin D deficient participants no significant association between serum 25(OH)D concentrations and risk of falls was observed. One case-control study reported no significant association between serum 25(OH)D concentrations and risk of falls after adjusting for serum PTH.

Ottawa EPC Report: Performance measures - Postmenopausal women or elderly men

Overall, there is inconsistent evidence for an association of serum 25(OH)D concentrations with performance measures. In studies that reported an association, specific concentrations below which, declines in performance measures were increased, ranged from 50 to 87 nmol/L.

Seven studies (three RCTs and four cohorts) assessed the relation between 25(OH)D concentrations and performance related measures. Two of the three RCTs and two of the four cohorts reported an association between 25(OH)D concentrations and performance measures. The other studies did not find an association between 25(OH)D concentrations and performance measures.

Additional RCTs published after the Ottawa EPC report

We identified three additional RCTs (published after the Ottawa EPC report)80–82 that examined the effect of either vitamin D_2_ or D_3_ supplementation on total fractures, falls, or performance in elderly populations (≥71 years old). All three RCTs were rated C. In two of the three RCTs80,81 calcium supplementation (800 or 1200 mg/d) was given to all participants. Baseline serum 25(OH)D concentrations were less than 40 nmol/L. The other RCT did not provide any information on background calcium intake or baseline serum 25(OH)D concentrations.82 All three RCTs reported no significant reduction in the risk of total fracture or falls in elderly populations at daily vitamin D doses ranging from 400 IU to 822 IU.80–82 Only one of the three new RCTs among elderly reported data on performance measures. Vitamin D supplementation (400 IU/d) improved gait speed and body sway in healthy elderly subjects.80

Findings by life stage

- 0–6 mo Not reviewed
- 7 mo–2 y Not reviewed
- 3–8 y Not reviewed
- 9–18 y Not reviewed
- 19–50 y No data
- 51–70 y The Ottawa EPC report concluded that the associations between serum 25(OH)D concentrations and risk of fractures, falls, and performance measures are inconsistent. There were no new data since the Ottawa report
- ≥71 y Findings from three new RCTs did not show significant effects of either vitamin D_2_ or D_3_ supplementation (daily doses ranged from 400 IU to 822 IU) in reducing the risk of total fractures or falls among men and women in this life stage.
- Postmenopause The Ottawa EPC report concluded that the associations between serum 25(OH)D concentrations and risk of fractures, falls, and performance measures are inconsistent. There were no new data since the Ottawa report
- Pregnant & lactating women Not reviewed

### Vitamin D and all-cause Mortality

Synopsis

This synopsis is based on our reanalysis of a systematic review of RCTs on vitamin D supplementation for mortality.^i^ In addition, it summarizes four observational studies on the association of vitamin D and all-cause mortality.

i Numerical data were extracted from previous systematic reviews –no additional studies were identified. For this reason, we did not appraise studies for their methodological quality.

Three RCTs from the previous systematic review and an additional C rated RCT were included in our reanalysis. Three used daily doses that ranged between 400 and 880 IU, and one used 100,000 IU every 3 months. Our meta-analysis of the 4 RCTs (13,833 participants) shows absence of significant effects of vitamin D supplementation on all-cause mortality (RR = 0.97, 95 percent CI: 0.92, 1.02; random effects model). There is little evidence for between-study heterogeneity in these analyses.

One cohort study (rated B for methodological quality) found a significant trend for lower odds for death with increasing 25(OH)D concentrations. Three other cohort studies did not find a significant association between 25(OH)D concentrations and all-cause mortality. These three studies were rated C for their methodological quality.

The above are applicable to older (50–70 y) and elderly (≥71 y) men and women (mean age was >70 y in the included studies).

Detailed presentation

(Tables 37, 38 & 39)

Table 37 Summary of systematic review on vitamin D supplementation and all-cause mortality

Author Year [PMID] | | Autier 2007^83^ [17846391]
Design (Search Years) | | Randomized controlled trials (1992–2006)
Population | | Community dwelling or institutionalized adults
Intervention (Exposure) and Comparator | | Supplementary vitamin D (at least 1000 mg/d) without calcium vs. placebo or no treatment
Results | | 18 trials of combined vitamin D and vitamin D + calcium RR: 0.93 (95% CI 0.87, 0.99); favoring vitamin D (± calcium) supplementation Statistically homogeneous In our reanalysis we and excluded 3 of 18 trials and separated studies with vitamin D only from those with vitamin D and calcium combination. For details and results of our reanalysis, see text.
Comments | | See text in vitamin D and vitamin D + calcium sections for reanalyses of the separated trials. Study participants, vitamin D assays, and vitamin D status are not described in detail.
AMSTAR Criteria
A priori design? | Yes | Study quality assessment performed? | No
Two independent reviewers? | No | Study quality appropriately used in analysis? | NA
Comprehensive literature search? | Yes | Appropriate statistical synthesis? | Yes
All publication types and languages included? | Yes | Publication bias assessed? | No
Included and excluded studies listed? | No | Conflicts of interest stated? | Yes
Study characteristics provided? | Yes | The meta-analysis did not perform quality assessment (neither using individual quality items nor using quality scores)

Table 38 Vitamin D and all-cause mortality: Characteristics of cohort studies

Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Confounders/Effect Modifiers Adjusted
Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV exposure | Lifestyle
Jia 2007^90^ UK (57°N) [17442130] | - Health status; - Age range, y; - Male (%) | Not terminally ill or demented>75 52 | Assay methodSeason blood drawn | RIA ND | Comparison of various 25(OH)D concentration categories | | X | | X | X | X
Shambrook 2004 & 2006^91,92^ FREE^A^ Australia (33°S) [15531500 &16598375] | - Health status; - Age range, y; - Male (%) | Not bedridden>65 22 | Assay methodSeason blood drawn | RIA (Diasorin) ND | Association with log 25(OH)D | | X | | X
Visser 2006^93^ Longitudinal Aging Study Netherlands (52°N) [16960177] | - Health status; - Age range, y; - Male(%) | General population^B^>65 51 | Assay methodSeason blood drawn | Competitive protein binding ND | Comparison of various 25(OH)D concentration categories | | X | X | | | X
Melamed 2008^47^ NHANES III US (various) [18695076] | - Health status; - Age mean (range), y; - Male (%) | General population 45 (>=20) 46 | Assay methodSeason blood drawn | RIA (Dia sorin) ND | Comparison of various 25(OH)D concentration categories | X | X | X | X | X | X

A Fracture Risk Epidemiology in the Elderly

B ~40% with CVD and ~60% arthritis

Table 39 Vitamin D and all-cause mortality: Results of cohort studies

Author Year Study Name Location (Latitude) [PMID] | Age range, sex | Outcome | Followup Duration (Time to Dx) | Vit D Measure | Concentration, nmol/L | No. of Cases | No. in Category | Adjusted OR | 95% CI | P for trend | Study Quality
Jia 2007^90^ UK (57°N) [17442130] | >75, both sexes | Mortality | 69 | 25(OH)D | 6.0–23.0 (M)/7.0–19.0 (F) | 41 | 75 | 1.74 | 0.91, 3.34 | 0.03 | B
Jia 2007^90^ UK (57°N) [17442130] | >75, both sexes | Mortality | 69 | 25(OH)D | 23.1–30.0 (M)/29.1–24.0 (F) | 34 | 86 | 1.40 | 0.73, 2.70 | 0.03 | B
Jia 2007^90^ UK (57°N) [17442130] | >75, both sexes | Mortality | 69 | 25(OH)D | 30.1–37.0 (M)/24.1–30.2 (F) | 21 | 80 | 0. 90 | 0.45, 1.79 | 0.03 | B
Jia 2007^90^ UK (57°N) [17442130] | >75, both sexes | Mortality | 69 | 25(OH)D | 37.1–47.0 (M)/30.3–39.0 (F) | 17 | 78 | 0.80 | 0.39, 1.62 | 0.03 | B
Jia 2007^90^ UK (57°N) [17442130] | >75, both sexes | Mortality | 69 | 25(OH)D | 47.1–82.0 (M)/39.1–82.0 (F) | 16 | 79 | 1.00 | Reference | 0.03 | B
Shambrook 2004 & 2006^91,92^ FREE^A^ Australia (33°S) [15531500 & 16598375] | >65, both sexes | Mortality | 27 | 25(OH)D | NA | 559 | 1112 | 0.87^B^ | 0.75, 1.01 | nd | C
Visser 2006^93^ Longitudinal Aging Study Netherlands (52°N) [16960177] | >65, both sexes | Mortality | 72 | 25(OH)D | <25 | 66 | 127 | 1. 28 | 0.85, 1.92 | 0.19 | C
Visser 2006^93^ Longitudinal Aging Study Netherlands (52°N) [16960177] | >65, both sexes | Mortality | 72 | 25(OH)D | 25–49.9 | 42 | 462 | 1.00 | 0.72, 1.40 | 0.19 | C
Visser 2006^93^ Longitudinal Aging Study Netherlands (52°N) [16960177] | >65, both sexes | Mortality | 72 | 25(OH)D | 50–74.9 | 30 | 440 | 0.91 | 0.65, 1.26 | 0.19 | C
Visser 2006^93^ Longitudinal Aging Study Netherlands (52°N) [16960177] | >65, both sexes | Mortality | 72 | 25(OH)D | ≥75 | 29 | 231 | 1.00 | Reference | 0.19 | C
Melamed 2008^47^ NHANES III US (various) [18695076] | >20, both sexes | Mortality | 104 | 25(OH)D | <17.8 | nd | nd | 1.26 | 1.08, 1.46 | nd | C
Melamed 2008^47^ NHANES III US (various) [18695076] | >20, both sexes | Mortality | 104 | 25(OH)D | 17.8–24.3 | nd | nd | 1.06 | 0.89, 1.24 | nd | C
Melamed 2008^47^ NHANES III US (various) [18695076] | >20, both sexes | Mortality | 104 | 25(OH)D | 24.4–32.1 | nd | nd | 0.93 | 0.79, 1.10 | nd | C
Melamed 2008^47^ NHANES III US (various) [18695076] | >20, both sexes | Mortality | 104 | 25(OH)D | >32.1 | nd | nd | 1.00 | Reference | nd | C
Melamed 2008^47^ NHANES III US (various) [18695076] | >20, men only | Mortality | 104 | 25(OH)D | <17.8 | nd | nd | 1.04 | 0.83, 1.30 | nd | C
Melamed 2008^47^ NHANES III US (various) [18695076] | >20, men only | Mortality | 104 | 25(OH)D | 17.8–24.3 | nd | nd | 0. 94 | 0.75, 1.19 | nd | C
Melamed 2008^47^ NHANES III US (various) [18695076] | >20, men only | Mortality | 104 | 25(OH)D | 24.4–32.1 | nd | nd | 0.82 | 0.64, 1.05 | nd | C
Melamed 2008^47^ NHANES III US (various) [18695076] | >20, men only | Mortality | 104 | 25(OH)D | >32.1 | nd | nd | 1.00 | Reference | nd | C
Melamed 2008^47^ NHANES III US (various) [18695076] | >20, women only | Mortality | 104 | 25(OH)D | <17.8 | nd | nd | 1.55 | 1.15, 1.98 | nd | C
Melamed 2008^47^ NHANES III US (various) [18695076] | >20, women only | Mortality | 104 | 25(OH)D | 17.8–24.3 | nd | nd | 1.27 | 0.97, 1.66 | nd | C
Melamed 2008^47^ NHANES III US (various) [18695076] | >20, women only | Mortality | 104 | 25(OH)D | 24.4–32.1 | nd | nd | 1.16 | 0.87, 1.55 | nd | C
Melamed 2008^47^ NHANES III US (various) [18695076] | >20, women only | Mortality | 104 | 25(OH)D | >32.1 | nd | nd | 1.00 | Reference | nd | C
Melamed 2008^47^ NHANES III US (various) [18695076] | 20–65, both sexes | Mortality | 104 | 25(OH)D | <17.8 | nd | nd | 1.28 | 0.93, 1.76 | nd | C
Melamed 2008^47^ NHANES III US (various) [18695076] | 20–65, both sexes | Mortality | 104 | 25(OH)D | 17.8–24.3 | nd | nd | 1. 13 | 0.81, 1.56 | nd | C
Melamed 2008^47^ NHANES III US (various) [18695076] | 20–65, both sexes | Mortality | 104 | 25(OH)D | 24.4–32.1 | nd | nd | 0.81 | 0.58, 1.14 | nd | C
Melamed 2008^47^ NHANES III US (various) [18695076] | 20–65, both sexes | Mortality | 104 | 25(OH)D | >32.1 | nd | nd | 1.00 | Reference | nd | C
Melamed 2008^47^ NHANES III US (various) [18695076] | ≥65, both sexes | Mortality | 104 | 25(OH)D | <17.8 | nd | nd | 1.26 | 1.03, 1.54 | nd | C
Melamed 2008^47^ NHANES III US (various) [18695076] | ≥65, both sexes | Mortality | 104 | 25(OH)D | 17.8–24.3 | nd | nd | 0.99 | 0.82, 1.20 | nd | C
Melamed 2008^47^ NHANES III US (various) [18695076] | ≥65, both sexes | Mortality | 104 | 25(OH)D | 24.4–32.1 | nd | nd | 0.97 | 0.79, 0.82 | nd | C
Melamed 2008^47^ NHANES III US (various) [18695076] | ≥65, both sexes | Mortality | 104 | 25(OH)D | >32.1 | nd | nd | 1.00 | Reference | nd | C

A Fracture Risk Epidemiology in the Elderly

B Per unit change in the log-transformed concentration.

As mentioned in the Methods section, we updated and reanalyzed published meta-analyses of mortality outcomes. We drew our own conclusions based on our analyses. We also comment on the concordance of our conclusions with those of the published meta-analyses.

Relevant published systematic reviews of RCTs (with meta-analyses)

We identified two systematic reviews (with meta-analyses) of RCTs that summarized the effect of vitamin D supplementation with or without calcium on mortality.83,84 One systematic review (Avenell 2008) examined only trials on fall prevention, and briefly described results on mortality.84 The second meta-analysis (Autier 2007) focused specifically on mortality.83 It included all RCTs identified in the first, as well as additional trials (which were not eligible for the primary analysis of the Avenell 2008 systematic review, namely prevention of falls).83 Therefore, the Autier 2007 meta-analysis was used as the basis for our reanalysis.

Table 37 summarizes the findings of the Autier 2007 systematic review.

Additional identified RCTs (not included in published systematic reviews)

Lyons 2007 (n=3343, 24 percent males) used monthly supplementation with 100,000 IU of vitamin D_2_, orally for 3 years.82 The trial took place in South Wales (latitude ~52°N) and included older people (mean age 84 y) living in sheltered accommodation. The primary outcome was prevention of fractures. The Lyons 2007 RCT received grade “C” for the all-cause mortality outcome, because of inconsistencies in the reported data. This RCT is included in the reanalysis described below.

Reanalysis

We excluded 5 of 18 trials in the Autier 2007 meta-analysis: One trial was on patients with congestive heart failure,85 one was published only in abstract form,86 in one trial the controls also received supplementation with vitamin D, albeit with a smaller dose,87 and two trials used vitamin D injections.88,89 One additional eligible RCT (Lyons 2007)82 was identified and included in our meta-analysis.

Overall, four trials (13,899 patients) used only vitamin D supplementation without calcium. Among the four trials, sample sizes ranged from 2578 to 5292 participants. Followup periods ranged from 36 to 60 months. Vitamin D doses in most trials ranged between 400 and 830 IU per day.

Overall, there were no significant effects of vitamin D supplementation on mortality. The RR was 0.97 (95 percent CI 0.92, 1.02), with no evidence for between-study heterogeneity (P=0.39, I^2^=0 percent).

Cohort studies

We identified four prospective cohort studies described in 5 publications.47,90–93 The characteristics of the four cohorts are shown in Table 38. One was rated “B” 90 for methodological quality and the remaining were rated “C”.

Table 39 summarizes the findings of the four studies. Briefly, only Jia 2007^90^ found a statistically significant trend between increasing 25(OH)D concentrations and lower odds for all-cause mortality (P=0.03). However, none of the odds ratios of the different 25(OH)D categories was significant, and if anything, they suggest an U shaped relationship between 25(OH)D and mortality. All other cohorts did not find significant associations. Melamed 2008^47^ performed analyses in subgroups of men and women, and <65 or ≥65 years of age, and found no significant associations (Table 33).

Findings by life stage

- 0–6 mo No data
- 7 mo–2 y No data
- 3–8 y No data
- 9–18 y No data
- 19–50 y A subgroup analysis of people younger than 65 years in NHANES III (Melamed 2008) found no significant associations between 25(OH)D concentrations and all cause mortality.
- 51–70 y Overall, there were no significant effects of vitamin D supplementation on mortality.
  - In a random effects model meta-analysis of five RCTs (n=13,899) the summary RR was 0.97 (95 percent CI 0.92, 1.02), with no evidence for between-study heterogeneity (p=0.39, I^2^=0 percent). The mean participant age was more than 70 years in these RCTs.
  - Overall, data from four cohorts suggest no association between baseline 25(OH)D measurements and all-cause mortality (one cohort found a statistically significant trend for). A subgroup analysis of people aged 65 years or older in NHANES III (Melamed 2008) found no significant associations between 25(OH)D concentrations and all cause mortality.
- ≥71 y The above (51–70 y) are applicable.
- Postmenopause No data
- Pregnant & lactating women No data

### Vitamin D and Hypertension and Blood Pressure

We searched for systematic reviews and primary studies that evaluated associations between vitamin D supplementation or serum concentrations and incidence of hypertension and change in blood pressure. For the outcome incidence of hypertension, we reviewed RCTs and other longitudinal studies. For the outcome change in blood pressure, we reviewed only RCTs. The EPC and the TEP agreed that due to the large volume of literature, the limited resources would not be expended on reviewing observational studies for the surrogate outcome blood pressure. We included only studies of adults. Studies of pregnancy-related hypertension and blood pressure control are included in the “Pregnancy-related outcomes” section.

#### Hypertension

Synopsis

No systematic reviews evaluated the association between vitamin D intake or serum 25(OH)D concentrations and incidence of hypertension. A combined analysis of a small subset of the Health Professionals Follow-up (HPFS) and Nurses Health Studies (NHS) evaluated the association with serum 25(OH)D concentrations. The analysis found higher incidence of hypertension at 4 and 8 years in men with baseline 25(OH)D concentration less than 37.5 nmol/L (OR~3–6). In women, serum 25(OH)D concentrations less than 37.5 nmol/L also had a significantly higher incidence of hypertension at 4 years (OR~3), but not at 8 years (OR~1.5).

Detailed presentation

(Tables 40 & 41)

Table 40 Vitamin D and hypertension: Characteristics of cohort studies

Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV exposure | Lifestyle | Comments
Forman 2007^94^ HPFS, NHS US (various) [17372031] | - Health status; - Mean age (SD), y; - Male (%) | Any Men 65 (8) Women 57 (7) 34 | Assay methodSeason blood drawn | RIA All | Hypertension incidence stratified by 25(OH)D categories (2 and 3 categories) | | X | X | | | X
Forman 2008^95^ NHS 2 US (various) [18838623] | - Health status; - Mean age (SD), y; - Male (%) | No HTN, CVD, DM, obesity, cancer 43 (40–46) 0 | Assay methodSeason blood drawn | EIA All | Hypertension incidence stratified by 25(OH)D categories (2 and 3 categories) | X | X | X | | X

Table 41 Vitamin D and hypertension: Results of cohort and nested case control studies

Author Year Study Name [PMID] | Mean (SD) Age, Sex | Outcome (n/N; Incidence) | Followup Duration | Vit D Measure | Concentration, nmol/L | No. of Cases | No. in Category | Adjusted OR | 95% CI | P for Trend | Study Quality
Men
Forman 2007^94^ HPFS [17372031] | 65 (8), Men | Hypertension (61/613; 0.100) | 4 y | 25(OH)D | <37.5 | 6 | 33 | 6.13 | 1.00, 37.8^*^ | nd | B
Forman 2007^94^ HPFS [17372031] | 65 (8), Men | Hypertension (61/613; 0.100) | 4 y | 25(OH)D | 37.5–75 | 33 | 247 | 1.12 | 0.51, 2.48 | nd | B
Forman 2007^94^ HPFS [17372031] | 65 (8), Men | Hypertension (61/613; 0.100) | 4 y | 25(OH)D | ≥75 | 22 | 233 | 1 | Reference | nd | B
Forman 2007^94^ HPFS [17372031] | 65 (8), Men | Hypertension (61/613; 0.100) | 4 y | 25(OH)D | <37.5 | 6 | 33 | 5.68 | 1.01, 32.3^*^ | <0.05 | B
Forman 2007^94^ HPFS [17372031] | 65 (8), Men | Hypertension (61/613; 0.100) | 4 y | 25(OH)D | ≥37.5 | 55 | 580 | 1 | Reference | <0.05 | B
Forman 2007^94^ HPFS [17372031] | 65 (8), Men | Hypertension (131/613; 0.214) | 8 y | 25(OH)D | <37.5 | 9 | 33 | 3.53 | 1.02, 12.3^*^ | nd | B
Forman 2007^94^ HPFS [17372031] | 65 (8), Men | Hypertension (131/613; 0.214) | 8 y | 25(OH)D | 37.5–75 | nd | 247 | nd | nd | nd | B
Forman 2007^94^ HPFS [17372031] | 65 (8), Men | Hypertension (131/613; 0.214) | 8 y | 25(OH)D | ≥75 | nd | 233 | 1 | Reference | nd | B
Forman 2007^94^ HPFS [17372031] | 65 (8), Men | Hypertension (131/613; 0.214) | 8 y | 25(OH)D | <37.5 | 9 | 33 | 3.03 | 0.94, 9.76 | NS | B
Forman 2007^94^ HPFS [17372031] | 65 (8), Men | Hypertension (131/613; 0.214) | 8 y | 25(OH)D | ≥37.5 | 124 | 580 | 1 | Reference | NS | B
Women
Forman 2008^95^ NHS 2 [18838623] | 43 (40–46, range), Women | Hypertension (742 cases; 742 controls) Nested case control | ~7 y | 25(OH)D | 41.75 (15.5–52.5) | 208 | 371 | 1.66 | 1.11, 2.48 | 0.01 | B
Forman 2008^95^ NHS 2 [18838623] | 43 (40–46, range), Women | Hypertension (742 cases; 742 controls) Nested case control | ~7 y | 25(OH)D | 59.5 (52.75–66.25) | 188 | 370 | 1.55 | 1.07, 2.23 | 0.01 | B
Forman 2008^95^ NHS 2 [18838623] | 43 (40–46, range), Women | Hypertension (742 cases; 742 controls) Nested case control | ~7 y | 25(OH)D | 73.0 (66.5–80.5) | 195 | 374 | 1.52 | 1.06, 2.18 | 0.01 | B
Forman 2008^95^ NHS 2 [18838623] | 43 (40–46, range), Women | Hypertension (742 cases; 742 controls) Nested case control | ~7 y | 25(OH)D | 94.75 (80.75–224) | 151 | 369 | 1 | Reference | 0.01 | B
Forman 2007^94^ NHS [17372031] | 57 (7), Women | Hypertension (129/1198; 0.108) | 4 y | 25(OH)D | <37.5 | 11 | nd^A^ | 2.67 | 1.05, 6.79^*^ | nd | B
Forman 2007^94^ NHS [17372031] | 57 (7), Women | Hypertension (129/1198; 0.108) | 4 y | 25(OH)D | 37.5–75 | 60 | nd | 0.85 | 0.53, 1.34 | nd | B
Forman 2007^94^ NHS [17372031] | 57 (7), Women | Hypertension (129/1198; 0.108) | 4 y | 25(OH)D | ≥75 | 58 | nd | 1 | Reference | nd | B
Forman 2007^94^ NHS [17372031] | 57 (7), Women | Hypertension (129/1198; 0.108) | 4 y | 25(OH)D | <37.5 | 11 | nd | 2.98 | 1.24, 7.20^*^ | <0.05 | B
Forman 2007^94^ NHS [17372031] | 57 (7), Women | Hypertension (129/1198; 0.108) | 4 y | 25(OH)D | ≥37.5 | 118 | nd | 1 | Reference | <0.05 | B
Forman 2007^94^ NHS [17372031] | 57 (7), Women | Hypertension (274/613; 0.229) | 8 y | 25(OH)D | <37.5 | 20 | nd^A^ | 1.70 | 0.92, 3.16 | nd | B
Forman 2007^94^ NHS [17372031] | 57 (7), Women | Hypertension (274/613; 0.229) | 8 y | 25(OH)D | 37.5–75 | nd | nd | nd | nd | nd | B
Forman 2007^94^ NHS [17372031] | 57 (7), Women | Hypertension (274/613; 0.229) | 8 y | 25(OH)D | ≥75 | nd | nd | 1 | Reference | nd | B
Forman 2007^94^ NHS [17372031] | 57 (7), Women | Hypertension (274/613; 0.229) | 8 y | 25(OH)D | <37.5 | 20 | nd | 1.42 | 0.79, 2.56 | NS | B
Forman 2007^94^ NHS [17372031] | 57 (7), Women | Hypertension (274/613; 0.229) | 8 y | 25(OH)D | ≥37.5 | 254 | nd | 1 | Reference | NS | B

* Statistically significant (P<0.05)

A Due to formatting error in study table, no data on numbers of women in each category.

One analysis (methodological quality B) evaluated the incidence of hypertension in a combined set of 613 men from the HPFS and 1198 women from the NHS who had serum 25(OH)D concentrations measured.94 The men were on average 65 years old and the women 57 years old. Among the men at 4 years, those with serum 25(OH)D concentrations less than 37.5 nmol/L were significantly more likely to have new onset hypertension than either men with 25(OH)D concentrations above 75 nmol/L (OR=6.1) or above 37.5 nmol/L (OR=5.7). The association remained significant at 8 years, although with a smaller effect size (OR=3.5 and 3.0, respectively). In women, a similar, though weaker, effect was seen at 4 years, such that those with 25(OH)D concentrations less than 37.5 nmol/L were significantly more likely to have new onset hypertension than either women with 25(OH)D concentrations above 75 nmol/L (OR=2.7) or above 37.5 nmol/L (OR=3.0). However, this effect was smaller and nonsignificant at 8 years (OR=1.7 and 1.4, respectively). The study was limited primarily by its inclusion of only a relatively small subset of participants and its reliance on self-reported hypertension without assessment of blood pressure measurements.

In the second analysis by the same investigators, the NHS 2 study was analyzed for the association between serum 25(OH)D concentration and hypertension as a nested case-control study.95 These women were on average 43 years old. Cases and controls (per the 2005 biennial questionnaire) were chosen from among those women without hypertension, cardiovascular disease, diabetes, obesity, or cancer at baseline (blood samples drawn from 1997 to 1999). After approximately 7 years, a statistically significant trend was found such that women in the three quartiles with serum 25(OH)D concentrations of 80.5 nmol/L or less were about 50 to 60 percent more likely to develop hypertension than those women with higher serum concentrations of 25(OH)D (adjusted OR = 1.52 to 1.66, each of which was statistically significant compared to the highest quartile). The study was graded methodological quality B for similar reasons as the analysis of the HPFS and NHS studies.

Findings per vitamin D concentration

The HPFS and NHS studies were analyzed with 25(OH)D cutpoints of 37.5 and 75 nmol/L. Significant associations were found for those with serum concentrations below 37.5 nmol/L. The NHS 2 study was analyzed with 25(OH)D quartiles, such that significant associations were found for those with serum concentrations of 80.5 nmol/L or less.

Findings per age and sex

See above Detailed presentation of the HPFS and NHS for the separate analyses by sex. No subgroup analyses were reported by life stage. The participants in the studies were approximately 40 to 80 years old.

Findings by life stage

- 0–6 mo Not reviewed
- 7 mo–2 y Not reviewed
- 3–8 y Not reviewed
- 9–18 y Not reviewed
- 19–50 y The NHS 2 included all women within the life stage. After approximately 7 years, those with serum 25(OH)D concentrations of 80.5 nmol/L or less were about 50 to 60 percent more likely to develop hypertension.
- 51–70 y HPFS and NHS included participants mostly within this life stage. In men and women, the study found higher incidence of hypertension at 4 years followup in those with serum 25(OH)D concentrations less than 37.5 nmol/L; at 8 years, the association was significant only for men.
- ≥71 y A minority of the men and few of the women appear to have been in this life stage. No unique conclusions are possible for this life stage separate from those for people 51 to 70 years.
- Postmenopause The majority of the women in NHS were postmenopausal. A significant association between serum 25(OH)D concentrations less than 37.5 nmol/L and increased hypertension was found at 4 years, but not 8 years followup.
- Pregnant & lactating women Not reviewed

#### Vitamin D and blood pressure

Synopsis

No qualified systematic reviews have evaluated the association between vitamin D intake or serum 25(OH)D concentrations and changes in blood pressure. Three trials from Germany, UK, and India compared different doses of vitamin D (800 IU daily, a single dose of 100,000 IU, or 120,000 IU every 2 weeks) with placebo, with or without supplemental calcium in both groups. The study participants also varied: either older men, older men and women, or men mostly in their 40s. Both recruited older adults (over 63 or 70 years). All trials reported no significant effect on diastolic blood pressure. The A quality British study of a single dose of vitamin D 100,000 IU found no difference in systolic blood pressure after 5 weeks. The B quality German study found a significant net reduction of 7 mm Hg after 8 weeks in older women taking vitamin D 800 IU daily. The B quality Indian study of obese men mostly in their 40s, found a nearly significant net increase of 4 mm Hg after 6 weeks of vitamin D 120,000 IU every 2 weeks. No long term data were available.

Detailed presentation

(Tables 42 & 43)

Table 42 Vitamin D and blood pressure: Characteristics of RCTs

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Scragg 1995^96^ Cambridge, UK (52°N) [7498100] | - Health status; - Mean age (range), y; - Male (%) | No HTN 70 (63–76) 46% | 25(OH)D: 34.5 nmol/L (treatment group), 32.25 nmol/L (control group) | Vit D_3_ 100,000 IU (2.5 mg) one-time dose vs. Placebo | nd | Complete trial performed in winter
Pfeifer 2001^97^ Lower Saxony, Germany (52°N) [11297596] | - Health status | Healthy, low Vit D | 25(OH)D < 50 nmol/L | Vit D_3_ + Ca supplement vs. Ca supplement | 95±12% for the Ca tablets and 96±10% for the Vit D_3_ + Ca tablets (pill counting)
Pfeifer 2001^97^ Lower Saxony, Germany (52°N) [11297596] | - Mean age (range), y; - Male (%) | 75 (70–86) 0 | 25(OH)D < 50 nmol/L | Vit D_3_ + Ca supplement vs. Ca supplement | 95±12% for the Ca tablets and 96±10% for the Vit D_3_ + Ca tablets (pill counting)
Nagpal 2009^51^ New Delhi, India (28.5°N) [19125756] | - Health status; - Mean age (SD), y; - Male (%) | Healthy, obese 44 (8) 100% | 25(OH)D: 36.5 nmol/L (treatment group), 30.0 nmol/L (control group) | Vit D_3_ 120,000 IU every 2 weeks vs. Placebo | 100% (implied); supervised home visits | Excluded subjects who refused subsequent blood draws

Table 43 Vitamin D and blood pressure: Results of RCTs

Author Year Study Name [PMID] | Age Range, Sex | Outcome | 1°/2° | Mean Followup | Interventions, Daily Dose | No. Analyzed | Unit | Baseline | Change | Change 95% CI | Net Diff | Net Diff 95% CI | P Btw | Study Quality
SYSTOLIC BLOOD PRESSURE
Scragg 1995^96^ UK [7498100] | 63–76 y, Both | SBP | 1° | 5 wk | Vit D_3_ 100,000 IU (2.5 mg), 1 dose | 95 | mm Hg | 149 | −5 | −14.4, 4.4^A^ | 0 | −4.2, 4.2^A^ | 0.81 | A
Scragg 1995^96^ UK [7498100] | 63–76 y, Both | SBP | 1° | 5 wk | Placebo | 94 | | 147 | −5 | −17.9, 7.9^A^ | | | | A
Pfeifer 2001^97^ Germany [11297596] | 70–86 y, Women | SBP | 1° | 8 wk | Vit D_3_ 800 IU +Ca carbonate 1200 mg | 73 | mm Hg | 144.1 | −13.1 | nd | −7.4 | −13.6, −1.2^A^ | 0.02 | B
Pfeifer 2001^97^ Germany [11297596] | 70–86 y, Women | SBP | 1° | 8 wk | Ca carbonate 1200 mg | 72 | | 140.6 | −5.7 | nd | | | | B
Nagpal 2009^51^ New Delhi, India [19125756] | 44 (8, SD) Men | SBP | 2° | 6 wk | Vit D_3_ 120,000 IU every 2 wk | 35 | mm Hg | 124 | +0.6 | −2.7, 3.9 | +4.0 | −0.02, 8.0 | 0.06 | B
Nagpal 2009^51^ New Delhi, India [19125756] | 44 (8, SD) Men | SBP | 2° | 6 wk | Placebo | 36 | | 124 | −3.4 | −5.8, −1.0 | | | | B
DIASTOLIC BLOOD PRESSURE
Scragg 1995^96^ UK [7498100] | 63–76 y, Both | DBP | 1° | 5 wk | Vit D_3_ 100,000 IU (2.5 mg), 1 dose | 95 | mm Hg | 82 | −1 | −6.8, 4.8^A^ | 0 | −2.8, 2.8^A^ | 0.92 | A
Scragg 1995^96^ UK [7498100] | 63–76 y, Both | DBP | 1° | 5 wk | Placebo | 94 | | 82 | −1 | −6.8, 4.8^A^ | | | | A
Pfeifer 2001^97^ Germany [11297596] | 70–86 y, Women | SBP | 1° | 8 wk | Vit D_3_ 800 IU +Ca carbonate 1200 mg | 73 | mm Hg | 84.7 | −7.2 | nd | −0.3 | −0.7, −0.1^A^ | 0.10 | B
Pfeifer 2001^97^ Germany [11297596] | 70–86 y, Women | SBP | 1° | 8 wk | Ca carbonate 1200 mg | 72 | | 82.6 | 6.9 | nd | | | | B
Nagpal 2009^51^ New Delhi, India [19125756] | 44 (8, SD) Men | SBP | 2° | 6 wk | Vit D_3_ 120,000 IU every 2 wk | 35 | mm Hg | 78 | +0.4 | −2.1, 3.0 | +1.7 | −1.5, 4.9 | 0.31 | B
Nagpal 2009^51^ New Delhi, India [19125756] | 44 (8, SD) Men | SBP | 2° | 6 wk | Placebo | 36 | | 77 | −1.3 | −3.2, 0.7 | | | | B

A Estimated from available data

The A quality trial of single-dose vitamin D, performed in Cambridge, UK, recruited older adults (63 to 76 years, mean 70 years) who were not taking antihypertensive medications.96 During the winter, they were given either a one-time dose of vitamin D_3_ (100,000 IU [2.5 mg]) or placebo, and blood pressure was rechecked at 5 weeks. In both study arms, systolic and diastolic blood pressures fell by equal amounts, resulting in no net difference between vitamin D supplemented and placebo groups. No subgroup analyses were reported.

The German B quality trial of supplementation with combined vitamin D and calcium versus calcium alone recruited older women (70 to 86 years) without severe hypertension.97 For 8 weeks, the women took either vitamin D_3_ 800 IU and calcium carbonate 1200 mg or calcium carbonate 1200 mg alone daily. Systolic blood pressure decreased by 13 mm Hg in those supplemented with vitamin D and calcium compared with a 6 mm Hg decrease in those taking calcium alone (P=0.02). Diastolic blood pressure declined by 7 mm Hg in both groups. No subgroup analyses were reported. The study was limited by inadequate reporting of its study methods and lack of blinding.

The Indian B quality study compared every other week vitamin D_3_ supplementation 120,000 IU with placebo for 3 weeks in generally healthy but obese men without hypertension.51 The men who received the vitamin D supplements had a net increase in systolic blood pressure of 4 mm Hg, which was close to statistically significant (P=0.06), but no significant difference in diastolic blood pressure. The study was limited by a high dropout rate (26 percent).

Findings per intake level

No conclusions can be reached about an intake level threshold. In individual trials, a single dose of 100,000 IU of cholecalciferol had no significant effect on systolic and diastolic blood pressure after 5 weeks, a daily dose of vitamin D_3_ 800 IU together with calcium significantly lowered systolic blood pressure more than calcium alone, but every other week vitamin D_3_ 120,000 IU resulted in a nearly statistically significant increase in systolic blood pressure.

Findings per age and sex

No conclusions can be reached about differences in effect based on age or sex. The study of older women found a significant decrease in systolic blood pressure with relatively low dose

Findings by life stage

- 0–6 mo Not reviewed
- 7 mo–2 y Not reviewed
- 3–8 y Not reviewed
- 9–18 y Not reviewed
- 19–50 y A single study of men in this life stage found a near significant increase in systolic blood pressure with vitamin D and no effect on diastolic blood pressure.
- 51–70 y One trial included people with an average age of 70 years, implying that about half were within this life stage. No significant effect on blood pressure was found of a single large dose of vitamin D.
- ≥71 y Both trials included people within this life stage. The trial of people with an average age of 70 years found no significant effect of a single large dose of vitamin D. The single trial of women over age 70 years found a significant benefit for systolic blood pressure for vitamin D_3_ 800 IU and calcium carbonate 1200 mg compared with calcium carbonate 1200 mg alone.
- Postmenopause The women in both trials were postmenopausal. See the ≥71 y life stage.
- Pregnant & lactating women Not reviewed

### Vitamin D and Bone Mineral Density or Bone Mineral Content

For bone health outcomes (e.g., bone mineral density, fracture, fall or muscle strength), we relied on a recent comprehensive systematic review performed by the Ottawa EPC (Table 28).6 Because the Ottawa’s EPC report did not have separate analyses on the effect of vitamin D supplementation alone, the results for the effect of vitamin D alone or in combination with calcium supplementation are presented in “Combined vitamin D and Calcium” section.

The Ottawa EPC report was updated with literature published between January 2006 and September 2008, selected according to our eligibility criteria. For adults, we included only bone mineral density (BMD) indices. For children, we included only bone mineral content (BMC) indices. Only RCTs with duration more than 1 year qualified for inclusion.

Synopsis

The Ottawa EPC report concluded that observational studies suggested a correlation between higher serum 25(OH)D concentrations and larger values of BMC indices for older children and adolescents (6 months through 18 years old). Furthermore, Based on results of the observational studies, there is fair evidence to support an association between serum 25(OH)D and BMD or changes in BMD at the femoral neck in postmenopausal women and elderly men. However, there was discordance between the results from RCTs and the majority of observational studies.6 Three new RCTs identify from our updated search all showed no significant effects of vitamin D supplementation on BMC or BMD in children or adults, respectively.

Our updated search did not identify any new RCTs examining the effect of vitamin D on BMD and related outcomes in pregnant or lactating women.

Detailed presentation

(Tables 44 & 45)

Table 44 Vitamin D and bone mineral density: Characteristics of RCTs published after the Ottawa EPC report

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Zhu 2008^98^ Perth, Australia (32 °S) [18410225] | - Health status; - Mean age(SD), y; - Male(%) | nd (based on the inclusion and exclusion criteria, assume subjects were not very healthy but normal physical functioning) 77 (4.5) 0 | 25(OH)D: 44.3 nmol/L Ca: 1097 mg/d | Vit D_2_ 1000 IU/d + Ca citrate 1200 mg/d vs. Ca citrate 1200 mg/d | 86.7% and86.8% in the vitamin D and the control groups(tablet counting)
Andersen 2008^99^ Copenhagen, Denmark (55 N°) [18208636] | - Health status; - Mean age (range), y; - Male (%) | Healthy Adolescent girls: 12.2 (10.1–14.7) Women: 36.2 (18.1–52.7) Men: 38.3 (17.9–63.5) 42 | 25(OH)D: Adolescent girls: 11 nmol/L Women: 12 nmol/L Men: 21 nmol/L Ca: Adolescent girls: 510 mg/d Women: 495 mg/d Men: 548 mg/d | Vit D3 400 IU/d, or Vit D3 800 IU/d vs. placebo | The median compliance was 85 (range 43–100), 92 (42–115) and 93 (33–105)% for girls, women, and men, respectively (pill counting) | Pakistani, living in Denmark. Compliance was lower for girls.
El-Hajj 2006^35^ Beirut, Lebanon (33°53′N) [16278262] | - Health status; - Mean age (range), y; - Male (%) | Healthy 13.2 (10–17) 0 | 25(OH)D: 34.9 nmol/L Ca: 677 mg/d | Weekly oral Vit D doses of 1400 IU (=Vit D 200 IU/d) or 14,000 IU (Vit D 2000 IU/d) vs. placebo | Placebo - 98%, Low dose group - 98%, High dose group - 97% (pill counting)

Table 45 Vitamin D and bone mineral density or bone mineral contents: Results of RCTs published after the Ottawa EPC report

Author Year Study Name Location (Latitude) [PMID] | Life Stage | Outcome | °/2° | Mean Followup, mo | Interventions, Daily Dose | No. Analyzed | Unit | Baseline | Change | Change 95% CI | Net Diff | Net Diff 95% CI | P Btw | Study Quality
Zhu 2008^98^ Perth, Australia (32 °S) [18410225] | 71+. Women only | Hip BMD | 1° | 12 | Vit D_2_ 1000 IU + Ca citrate 1200 mg | 123 | mg/cm^2^ | 851 | 0.5% | −0.09, 1.09 | 0.3% | nd | NS | A
Zhu 2008^98^ Perth, Australia (32 °S) [18410225] | 71+. Women only | Hip BMD | 1° | 12 | Ca citrate 1200 mg | 133 | | 826 | 0.2% | −0.19, 0.59 | | | | A
Andersen 2008^99^ Copenhagen, Denmark (55 N°) [18208636] | 18–53, Women only | Lumbar spine BMD | 1° | 12 | Vit D_3_ 400 | 30/21^A^ | mg/cm^2^ | 1.06 | 0% | nd | −1% | nd | NS | B
Andersen 2008^99^ Copenhagen, Denmark (55 N°) [18208636] | 18–53, Women only | Lumbar spine BMD | 1° | 12 | Vit D_3_ 800 | 30/21 | | 0.98 | 1% | nd | 0% | nd | NS | B
Andersen 2008^99^ Copenhagen, Denmark (55 N°) [18208636] | 18–53, Women only | Lumbar spine BMD | 1° | 12 | Placebo | 29/18 | | 0.99 | 1% | nd | | | | B
Andersen 2008^99^ Copenhagen, Denmark (55 N°) [18208636] | 18–64, Men only | Lumbar spine BMD | 1° | 12 | Vit D_3_ 400 | 25/19^A^ | mg/cm^2^ | 1.03 | 2% | nd | 0% | nd | NS | B
Andersen 2008^99^ Copenhagen, Denmark (55 N°) [18208636] | 18–64, Men only | Lumbar spine BMD | 1° | 12 | Vit D_3_ 800 | 31/26 | | 0.92 | 7% | nd | 5% | nd | NS | B
Andersen 2008^99^ Copenhagen, Denmark (55 N°) [18208636] | 18–64, Men only | Lumbar spine BMD | 1° | 12 | Placebo | 27/19 | | 1.03 | 2% | nd | | | | B
Andersen 2008^99^ Copenhagen, Denmark (55 N°) [18208636] | 10–15 y girls | BMC | 1° | 12 | Vit D_3_ 400 | 9/7^A^ | kg | 1.3 | 22% | nd | 7% | nd | NS | C^B^
Andersen 2008^99^ Copenhagen, Denmark (55 N°) [18208636] | 10–15 y girls | BMC | 1° | 12 | Vit D_3_ 800 | 9/7 | | 1.5 | 10% | nd | −5% | nd | NS | C^B^
Andersen 2008^99^ Copenhagen, Denmark (55 N°) [18208636] | 10–15 y girls | BMC | 1° | 12 | Placebo | 8/7 | | 1.7 | 15% | nd | | | | C^B^
El-Hajj 2006^35^ Beirut, Lebanon (33°N) [16278262] | 10–17 y girls | BMC | 1° | 12 | Vit D 2000 IU | 55 | kg | 1.2 | 6.2% | 4.7, 7.7 | 0.1% | −1.1, 2.0^C^ | NS | C
El-Hajj 2006^35^ Beirut, Lebanon (33°N) [16278262] | 10–17 y girls | BMC | 1° | 12 | Vit D 200 IU | 58 | | 1.1 | 6.1% | 4.6, 7.6 | 1.1% | −0.8, 3.2^C^ | NS | C
El-Hajj 2006^35^ Beirut, Lebanon (33°N) [16278262] | 10–17 y girls | BMC | 1° | 12 | Placebo | 55 | | 1.1 | 5.0% | 3.8, 6.2 | | | | C
El-Hajj 2006^35^ Beirut, Lebanon (33°N) [16278262] | Subgroup–Premenarcheal girls, mean age 10 y | BMC | 1° | 12 | Vit D 2000 IU | 14 | kg | 0.8 | 11.6% | 9.4, 13.8 | 4.2% | 0.7, 7.7^C^ | NS | C
El-Hajj 2006^35^ Beirut, Lebanon (33°N) [16278262] | Subgroup–Premenarcheal girls, mean age 10 y | BMC | 1° | 12 | Vit D 200 IU | 12 | | 0.7 | 11.4% | 9.1, 13.7 | 4.0% | 0.5, 7.5^C^ | NS | C
El-Hajj 2006^35^ Beirut, Lebanon (33°N) [16278262] | Subgroup–Premenarcheal girls, mean age 10 y | BMC | 1° | 12 | Placebo | 8 | | 0.8 | 7.4% | 4.7, 10.1 | | | | C

A Baseline/final sample size

B Downgraded to C because very small sample size (insufficient power) and no adjustments for confounders

C Estimated from available data

Ottawa EPC Report: Bone mineral content - Infants (0 through 12 months)

Overall, there is inconsistent evidence for an association between a specific serum 25(OH)D concentration and the bone health outcome BMC in infants. Of the two RCTs examining BMC, one demonstrated no significant benefit of higher serum 25(OH)D concentrations on radial bone mass while the other showed a transient increase of BMC compared to the unsupplemented group at 12 weeks but not 26 weeks. Of the three case-control studies, greater whole body BMC, was related to higher serum 25(OH)D concentrations.

Ottawa EPC Report: Bone mineral content or density - Older children (6 months through before puberty) and adolescents (the onset of puberty through 18 years)

Overall, there was fair evidence of an association between 25(OH)D concentrations and baseline BMD and change in BMD or BMC indices from the studies in older children and adolescents. However, the results from two RCTs of vitamin D supplementation have not confirmed a consistent benefit on BMD or BMC across sites and age groups.

There were seven studies in older children and adolescents (two RCTs, three cohorts, one case-control and one before-after study) that evaluated the relationship between serum 25(OH)D concentrations and BMC or BMD. In older children, there was one RCT, one prospective cohort and one before-after study. One RCT did not find an association between serum 25(OH)D concentrations and distal radial BMC. Two of three studies found an association between lower baseline serum 25(OH)D concentrations and lower BMC or BMD. The effect of bone size and muscle mass on these outcomes in relation to baseline serum 25(OH)D concentrations was not reported. One RCT demonstrated a significant relation between baseline serum 25(OH)D concentrations and baseline BMD of the lumbar spine, femoral neck and radius. However, only high dose supplementation with 14,000 IU/wk of vitamin D_3_ increased BMC of the total hip.

Ottawa EPC Report: Bone mineral density – Postmenopausal women and elderly men

Overall, there was discordance between the results from RCTs and the majority of observational studies that may be due to the limitations of observational studies to control for all relevant confounders. Five RCTs, and three cohort studies did not find an association between serum 25(OH)D concentrations and BMD or bone loss. Four cohort studies found a significant association between 25(OH)D concentrations and bone loss, which was most evident at the hip sites but the evidence for an association between 25(OH)D concentrations and lumbar spine BMD was weak. Six case-control studies suggested an association between 25(OH)D concentrations and BMD and the association was most consistent at the femoral neck BMD.

Based on the results from the observational studies, there is fair evidence to support an association between serum 25(OH)D and BMD or changes in BMD at the femoral neck. Specific circulating concentrations of 25(OH)D below which bone loss at the hip was increased ranged from 30–80 nmol/L.

Ottawa EPC Report: Bone mineral density - pregnant or lactating women

One cohort study did not find an association between serum 25(OH)D concentrations and change in BMD that occurred during lactation. Limitations in the study design and sources of bias highlight the need for additional research on vitamin D status in pregnancy and lactation, and the association with bone health outcomes.

Additional studies published after the Ottawa EPC report

One A quality RCT compared the effect of vitamin D_2_ supplementation on hip BMC in 256 elderly women between 70 and 90 years of age.98 All elderly women in this trial had normal physical functioning. They were randomly assigned to receive either vitamin D_2_ (1000 IU/d) plus calcium (1200 mg/d) supplement or calcium (1200 mg/d) supplement alone for one year. The mean baseline dietary calcium intake was 1097 mg/d and mean 25(OH)D concentration was 44.3 nmol/L. Total hip BMD increased significantly in both groups, with no difference between the vitamin D_2_ plus calcium and calcium alone groups (hip BMD change: vitamin D, +0.5 percent; control, +0.2 percent).

One B quality RCT analyzed 89 and 83 healthy adult women and men separately.99 The participants were Pakistani immigrants living in the Copenhagen area of Denmark (latitude 55 N°). Women and men were randomly assigned to receive either daily dose of 400 IU or 800 IU vitamin D_3_, or placebo for one year. For women, the mean baseline dietary calcium intake was 495 mg/d and mean 25(OH)D concentration was 12 nmol/L. For men, the mean baseline dietary calcium intake was 548 mg/d and mean 25(OH)D concentration was 21 nmol/L. At the end of study, in both women and men, there were no significant differences in lumbar spine BMD changes between the two doses of vitamin D_3_ (400 IU/d or 800 IU/d) and the placebo groups.

Two RCTs, both rated C, compared the effect of vitamin D supplementation on BMC in healthy girls, aged between 10 and 17 years old.35,99 First RCT analyzed 26 healthy girls, who were Pakistani immigrants primarily living in the Copenhagen area Denmark (latitude 55 N°).99 Girls were randomly assigned to receive either daily dose 400 IU or 800 IU vitamin D_3_, or placebo for one year. The mean baseline dietary calcium intake was 510 mg/d and mean 25(OH)D concentration was 11 nmol/L. At the end of study, there were no significant differences in whole body BMC changes between the two doses of vitamin D_3_ (400 IU/d or 800 IU/d) and the placebo groups. Second RCT analyzed 168 healthy girls, living in the Greater

Findings by life stage

- 0–6 mo The Ottawa EPC report concluded that there is inconsistent evidence for an association between a specific serum 25(OH)D concentration and the bone health outcome BMC in infants. There were no new data since the Ottawa report.
- 7 mo–2 y The Ottawa EPC report concluded that there was fair evidence of an association between 25(OH)D concentrations and baseline BMD and change in BMD or BMC indices from the studies in older children and adolescents. There were no new data since the Ottawa report.
- 3–8 y The Ottawa EPC report concluded that there was fair evidence of an association between 25(OH)D concentrations and baseline BMD and change in BMD or BMC indices from the studies in older children and adolescents. There were no new data since the Ottawa report.
- 9–18 y The Ottawa EPC report concluded that there was fair evidence of an association between 25(OH)D concentrations and baseline BMD and change in BMD or BMC indices from the studies in older children and adolescents. Two new RCTs enrolled only girls in this life stage. The results showed no significant differences in whole body BMC changes between either lower doses of vitamin D (200 or 400 IU/d) or higher dose of vitamin D (800 or 2000 IU/d) and the placebo groups.
- 19–50 y The Ottawa EPC report concluded that there was discordance between the results from RCTs and the majority of observational studies in postmenopausal women and elderly men. Based on results of the observational studies, there is fair evidence to support an association between serum 25(OH)D and BMD or changes in BMD at the femoral neck. One new RCT enrolled primarily men and women in this life stage. The results showed that there were no significant differences in lumbar spine BMD changes between the two doses of vitamin D_3_ (400 IU/d or 800 IU/d) and the placebo groups.
- 51–70 y The Ottawa EPC report concluded that there was discordance between the results from RCTs and the majority of observational studies in postmenopausal women and elderly men. Based on results of the observational studies, there is fair evidence to support an association between serum 25(OH)D and BMD or changes in BMD at the femoral neck. One new RCT enrolled some men in this life stage. The results showed that there were no significant differences in lumbar spine BMD changes between the two doses of vitamin D_3_ (400 IU/d or 800 IU/d) and the placebo groups.
- ≥71 y The Ottawa EPC report concluded that there was discordance between the results from RCTs and the majority of observational studies in postmenopausal women and elderly men. Based on results of the observational studies, there is fair evidence to support an association between serum 25(OH)D and BMD or changes in BMD at the femoral neck. One new RCT enrolled only elderly women in this life stage. The results showed that vitamin D_2_ supplementation (1000 IU/d) had no additional effect on hip BMD compared to calcium supplementation alone.
- Postmenopause There were no new data since the Ottawa report.
- Pregnant & lactating women There were no new data since the Ottawa report.

## Calcium and Health Outcomes

### Calcium and Growth

We reviewed systematic reviews and primary studies that evaluated relationships between calcium intake and growth parameters in infants and children.

Synopsis

One systematic review and three primary studies evaluated supplemental intake of calcium and growth parameters in infants and children. The systematic review with a meta-analysis of 17 RCTs did not find an effect on weight and height gain attributable to calcium supplement in children ranging from 3 to 18 years of age. Three additional primary studies reported similar findings. Overall, the studies reviewed did not find a relationship between supplemental calcium intake and growth parameters.

Detailed presentation

(Tables 46, 47 & 48)

Table 46 Summary of systematic review of calcium on growth in children

Author Year [PMID] | Winzenberg 2007^100^ [17636098]
Design (Search Years) | Randomized controlled trials (1966–2005)
Population | Children <18 y
Intervention (Exposure) and Comparator | Supplemental and dietary calcium 300–1200 mg/d vs. placebo
Results | 17 trials (2088 participants) Weighted mean difference: +0.14 (95% CI −0.28, +0.57) kg; favors control Weighted mean difference: +0.22 (95% CI −0.30, +0.74) cm; favors control No significant statistical heterogeneity
Comments | Post hoc analysis performed on trials identified for a meta-analysis of randomized controlled trials of calcium on bone outcomes
AMSTAR
A priori design? | Yes | Study quality assessment performed? | Yes
Two independent reviewers? | Yes | Study quality appropriately used in analysis? | No
Comprehensive literature search? | Yes | Appropriate statistical synthesis? | Yes
All publication types and languages included? | No | Publication bias assessed? | Yes
Included and excluded studies listed? | No | Conflicts of interest stated? | No
Study characteristics provided? | Yes | Unclear if all languages included; study quality assessed but not factored into the M-A

Table 47 Calcium and growth: Characteristics of primary studies

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV exposure | Lifestyle | Comments
Lorenzen 2006^101^ Denmark (55°N) [16400044] | - Health status; - Mean age (range/SD), y; - Male (%) | no specific health issue reported 13 0 | 88-item FFQ (no internal validation); dietary calcium: 957 mg/d; 25(OH)D: 34.5 nmol/L | Ca CO_3_ (Ca500 mg/d) X 1 y vs. placebo | x | X | x | | | | RCT; Danish surnames only
Lappe 2004^102^ Omaha, NE US (41°N) [15354150] | - Health status; - Mean age (range/SD), y; - Male (%) | healthy 9.5 0 | 3-d food record (no internal validation); dietary intake calcium: 819 mg/d; dietary vit D 180 IU/d (4.5 μg/d) | Calcium rich diet (~1656 mg/d) vs. usual diet (~961 mg/d); wt & ht change at 2 y | x | X | x | | | X | Post hoc of RCT on bone mass; 95% white, 5% black
Johnson 1994^103^ Washington DC, US (38°N) [8201444] | - Health status; - Mean age (range/SD), y; - Male (%) | pregnant; no DM, sickle, thalassemia, HbC disease 22 (39% 16–19) 0 | FFQ (no internal validation); calcium 933.4 mg/d | Relationship between maternal calcium intake and birth weight, height | | | | | | | Cohort study; all African American; Total Ca (from food)

Table 48 Calcium and growth: Results of primary studies

Author Year Study Name PMID | Life Stage | Outcome | 1°/2° | Mean Followup, Y | Interventions, Ca daily Dose | No. Analyzed | Unit | Baseline | Change | Change 95% CI | Net Diff | Net Diff 95% CI | P Btw | Study Quality
RCT
Lorenzen 2006^101^ (55°N) [16400044] | 9–18 female | wt in medium Ca intake group (1000–1304 mg/d) | 1° | 1 | 500 mg/d × 1 y | 30 | kg | 51.8 | 5.1 | 1.7, 8.5^A^ | 0.2 | −4.4, 4.9^A^ | NS | B
Lorenzen 2006^101^ (55°N) [16400044] | 9–18 female | wt in medium Ca intake group (1000–1304 mg/d) | 1° | 1 | Placebo | 30 | kg | 50.7 | 4.9 | 1.8, 8.0^A^ | | | | B
Lorenzen 2006^101^ (55°N) [16400044] | 9–18 female | wt in low Ca intake group (<713 mg/d) | 1° | 1 | 500 mg/d × 1 y | 30 | kg | 52.2 | 4.1 | 0.7, 7.5^A^ | 1.1 | −3.6, 5.8^A^ | NS | B
Lorenzen 2006^101^ (55°N) [16400044] | 9–18 female | wt in low Ca intake group (<713 mg/d) | 1° | 1 | Placebo | 30 | kg | 49.5 | 3.0 | −0.2, 6.2^A^ | | | | B
Lorenzen 2006^101^ (55°N) [16400044] | 9–18 female | ht in medium Ca intake group (1000–1304 mg/d) | 1° | 1 | 500 mg/d × 1 y | 30 | cm | 162.5 | 3.7 | 1.6, 5.8^A^ | −0.3 | −3.3, 2.8^A^ | NS | B
Lorenzen 2006^101^ (55°N) [16400044] | 9–18 female | ht in medium Ca intake group (1000–1304 mg/d) | 1° | 1 | Placebo | 30 | cm | 161.9 | 4.0 | 1.7, 6.3^A^ | | | | B
Lorenzen 2006^101^ (55°N) [16400044] | 9–18 female | ht in low Ca intake group (<713 mg/d) | 1° | 1 | 500 mg/d × 1 y | 30 | cm | 159.6 | 3.6 | 1.1, 6.1^A^ | 0.5 | −3.3, 4.3^A^ | NS | B
Lorenzen 2006^101^ (55°N) [16400044] | 9–18 female | ht in low Ca intake group (<713 mg/d) | 1° | 1 | Placebo | 30 | cm | 160.1 | 3.1 | 0.3, 5.9^A^ | | | | B
Post hoc analysis of an RCT on bone outcomes
Lappe 2004^102^ (41°N) [15354150] | 9–18 female | wt | 2° | 2 | Ca enriched diet (~1656 mg) | 27 | kg | 32.2 | 10.7 | 8.2, 13.2^A^ | −0.2 | −4.1, 3.7^A^ | NS | B
Lappe 2004^102^ (41°N) [15354150] | 9–18 female | wt | 2° | 2 | Usual diet (~961 mg) | 32 | kg | 33.2 | 10.9 | 7.9, 13.9^A^ | | | | B
Lappe 2004^102^ (41°N) [15354150] | 9–18 female | ht | 2° | 2 | Ca enriched diet (~1656 mg) | 27 | cm | 137 | 14 | 11.5, 16.5^A^ | 1 | −2, 4^A^ | NS | B
Lappe 2004^102^ (41°N) [15354150] | 9–18 female | ht | 2° | 2 | Usual diet (~961 mg) | 32 | cm | 138 | 13 | 11, 15^A^ | | | | B
Cohort
Johnson1994^103^ (38°N) [8201444] | 9–18 female; infant 0–6 mo | birth wt & length | 1° | until delivery | 322 African American women with a mean dietary calcium intake of 933 mg/d; “None of the food energy and nutrient intakes was significantly correlated with any of the pregnancy outcome measures”. No specific quantitative relationship between calcium intake and infant birth weight or length was reported. | | | | | | | | | C

A Estimated from reported data

0–6 months; 3–8 years; 9–18 years; pregnant women

One systematic review of RCTs of supplemental calcium on bone related outcomes in children (age 3–18 y) also examined changes in height and weight at followup.100 The systematic review (comprised of studies in Australia, China, Gambia, Israel, Switzerland, and US) conducted a meta-analysis of 17 RCTs with a total of 2088 subjects and found no significant difference in weight (weighted mean difference +0.14 kg (favors control)(95 percent CI −0.28, +0.57 kg)) and height gain (weighted mean difference +0.22 cm (favors control)(95 percent CI −0.30, +0.74 cm)) between those who were and those who were not supplemented. There was no significant statistical heterogeneity in the included studies. The calcium intake ranged from 300 to 1200 mg/d lasting from 0.7 to 4 years. The majority of the supplement used was calcium carbonate. This systematic review met seven of 11 AMSTAR^i^ quality checklist items.

i A measurement tool to assess the methodological quality of systematic reviews

Two primary studies rated B in methodological quality and one primary study rated C provided additional information. One RCT from Denmark randomly assigned 110 girls (mean age 13 years) with either low (<713 mg/d) or medium (1000 to 1304 mg/d) habitual calcium intake to a supplement of calcium 500 mg/d (calcium carbonate) or placebo for 1 year.101 There was no significant difference in height or weight gain among the groups at followup. One post hoc analysis of an RCT in Nebraska on bone mass analyzed 59 girls (mean age 9.5 years) who were randomly assigned to either a calcium enriched diet, supplying at least 1500 mg of calcium per day (~1656 mg/d), or usual diet (961 mg/d).102 There was no significant difference in weight gain at 2 years followup. A cohort study in Washington DC analyzed dietary intake data from 322 pregnant African American women (mean age 21.6 years; 39 percent 16–19 years) and found that “none of the food energy and nutrient intakes [mean calcium intake 933 mg ± 52 (SE)] was significantly correlated with any of the pregnancy outcome measures”. No specific quantitative relationship between calcium intake and infant birth weight or length was reported.103

Findings by life stage

- 0–6 mo A cohort study of dietary intake in 322 pregnant African American women found that calcium intake was not significantly correlated with any pregnancy outcome measures, including infant birth weight or length.
- 7 mo–2 y No study covered this life stage.
- 3–8 y One meta-analysis of 17 RCTs in children (age 3–18 y) found no significant difference in weight and height gain between those who were and those who were not supplemented at followup. The calcium intake ranged from 300 to 1200 mg/d lasting from 0.7 to 4 years.
- 9–18 y In addition to the findings from the above meta-analysis, two primary studies provided additional information. One RCT of calcium 500 mg/d (calcium carbonate) versus placebo for 1 year found no significant difference in height or weight gain among the 110 girls (mean age 13 years) at followup. A post hoc analysis of an RCT of calcium enriched diet (~1656 mg/d) versus usual diet (~961 mg/d) on bone mass found no significant difference in weight gain at 2 years followup in 59 girls (mean age 9.5 years).
- 19–50 y Not reviewed
- 51–70 y Not reviewed
- ≥71 y Not reviewed
- Postmenopause Not reviewed
- Pregnant & lactating women See 0–6 month results.

### Calcium and Cardiovascular Disease

Synopsis

No qualified systematic reviews evaluated the association between calcium intake and incidence of cardiovascular disease. No calcium intervention trials evaluated cardiovascular outcomes. Ten longitudinal cohort studies and one nested case-control study analyzed associations with various specific cardiovascular events. In all studies, baseline calcium intake, assessed by food frequency questionnaires, were analyzed as predictors of long-term cardiovascular outcomes. We point out where there were “suggestions” of associations in cases where P values were about 0.10 and/or there were consistent, though not statistically significant differences in risk compared to the lowest risk category of at least 20 percent.

Notably, the implied ranges of calcium intake within studied populations varied widely across studies. At one extreme, men and women in the Japan CC study had mean calcium intakes in the lowest quintile of 250 or 266 mg/day and in the highest quintile of 665 and 667 mg/day. The Japan PHC study and the Taiwanese CVD-FACTS study had similarly low calcium intake. The study with the highest calcium intake was the ATBC study of men in Finland. Median calcium intakes in the lowest and highest quintiles were 876 and 1916 mg/day, respectively; the overall median intake was 1379 mg/day.

Cardiovascular death was analyzed in two large studies analyzed, separately in men and women. Neither found a significant association between calcium intake and cardiovascular death after 9 or 28 years in either men or women.

Combined fatal and nonfatal cardiac events were analyzed in two large and one relatively small studies, in either both sexes together or just men. None found a significant association between calcium intake and cardiac events after 10 to 13 years.

Cardiac death was analyzed in three large and one relatively small studies, separately in men and women. Overall, no consistent significant association between calcium intake and cardiac death after 8, 9, 12, or 28 years of followup was found in the various studies, in either men or women. One study (the Iowa WHS) found a significant association between calcium intake of less than 696 mg/day and higher risk of ischemic heart disease death in white women aged 55 to 69 years.

Nonfatal myocardial infarction was analyzed by one large study of men. No significant association was found with calcium intake after 12 years of followup.

Total strokes were analyzed in five large and one relatively small studies, in both sexes combined, and separately for men and women. The studies had disparate findings. A Japanese and a Taiwanese study of men and women (40–59 y and ≥40 y, respectively) found progressively lower risks for stroke in people in higher quintiles of calcium intake after 13 and 11 years, respectively, in the setting of overall relatively low dietary calcium intake. A small Finnish study of both men and women (65–99 y) found no significant association after 10 years. The two studies of men (40 to 75 years old) found suggestions of associations (not statistically significant), though with trends in opposite directions; one suggested the highest risk for stroke in men with calcium intake below approximately 750 mg/day after 8 years; one suggested the highest risk for cerebral infarctions in men with calcium intake above about 1000 mg/day after 14 years. The study of women (32–57 y) found a nonsignificant trend after 14 years, but significantly higher stroke risk in those with calcium intake less than about 500 mg/day compared with women in the next two higher quintiles of calcium intake.

Fatal strokes were analyzed in one large cohort study and a nested case-control study, separately in men and women. None found a significant association between calcium intake and cardiac events after 10 to 13 years of followup.

Detailed presentation

(Tables 49 & 50, Figures 11 & 12)

Table 49 Calcium and cardiovascular outcomes: Characteristics of cohort studies^B^

Author Year Study Name Location (Latitude) [PMID] | Population | | Dietary Calcium intake | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Specific CVD Outcomes
Author Year Study Name Location (Latitude) [PMID] | Population | | Dietary Calcium intake | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV exposure | Lifestyle | Specific CVD Outcomes
Al-Delaimy 2003^107^ HPFS US (various) [12663277] | - Health status; - Mean age (SD), y; - Male (%) | No CVD 54 (9) 100 | - Dietary assessment method; - Internal validation? (y/n) | FFQ Yes | Outcome stratified by total Ca intake quintiles | X | X | X | X | | X | IHD MI Cardiac death Total Ca (both)
Ascherio 1998^109^ HPFS US (various) [9743511] | - Health status; - Mean age (range), y; - Male (%) | No CVD nd (40–75) 100 | - Dietary assessment method; - Internal validation? (y/n) | FFQ Yes | Outcome stratified by total Ca intake quintiles | X | X | X | X | | X | Stroke Total Ca (both)
Bostick 1999^110^ Iowa WHS Iowa (42°) [9921960] | - Health status; - Mean age (range), y; - Male (%) | No IHD 61 (55–69) 0 | - Dietary assessment method; - Internal validation? (y/n) | FFQ Yes | Outcome stratified by total Ca intake quartiles | X | X | X | X | | X | Cardiac death Total Ca(both)
Iso 1999^111^ NHS US (various) [10471422] | - Health status; - Mean age (range), y; - Male (%) | No CVD 46 (32–57) 0 | - Dietary assessment method; - Internal validation? (y/n) | FFQ No | Outcome stratified by total Ca intake quintiles | | X | | | | X | Stroke Total Ca (food)
Larsson 2008^112^ ATBC SW Finland (~60°N) [18332289] | - Health status; - Mean age (range), y; - Male (%) | No stroke 57 (50–69) 100 | - Dietary; - assessment method; - Internal validation? (y/n) | FFQ No | Outcome stratified by total Ca intake quintiles | X | X | X | X | | X | Stroke (cerebral infarct) Total Ca (food)
Marniemi 2005^48^ Turku Finland (60°N) [15955467] | - Health status; - Mean age (range), y; - Male (%) | Any 79 (65–99) 48% | - Dietary assessment method; - Internal validation? (y/n) | Interview No | Outcome stratified by total Ca intake tertiles | X | X | | | | X | MI Stroke Total Ca (both)
Ross 1997^113,A^ Shanghai China (31°N) [9236416] | - Health status; - Mean age(range), y; - Male (%) | Cases& controls nd (45–64) 100 | - Dietary assessment method; - Internal validation? (y/n) | FFQ Yes | Outcome stratified by total Ca intake tertiles | | X | X | X | | X | Fatal stroke Total Ca(food)
Umesawa2006^104^ Japan CC Japan (various) [16339476] | - Health status; - Mean age (range), y; - Male (%) | No CVD 56 (40–79) 39 | - Dietary assessment method; - Internal validation? (y/n) | FFQ No | Outcome stratified by total Ca intake quintiles | X | X | X | X | | X | Cardiac death Stroke death CVD death Total Ca(food)
Umesawa2008^106^ Japan PHC Japan (various) [18635855] | - Health status; - Mean age(range), y; - Male (%) | No CVD 49 (40–59) 48 | - Dietary assessment method; - Internal validation? (y/n) | FFQ Yes | Outcome stratified by total Ca intake quintiles | X | X | X | X | | X | CHD Stroke Total Ca(food)
van der Vijver1992^105^ Dutch civil servants Amsterdam Netherlands (52°) [1544755] | - Health status; - Mean age (range), y; - Male(%) | Any 52 (40–65) 51 | - Dietary assessment method; - Internal validation? (y/n) | FFQ No | Outcome stratified by total Ca intake quintiles | | X | X | | | X | Cardiac death CVD death Total Ca(food)
Weng2008^108^ CVD—FACTS Taiwan (22°-25°) [18988909] | - Health status; - Mean age(range), y; - Male(%) | No stroke, cancer 57 (≥40) 44 | - Dietary assessment method; - Internal validation? (y/n) | FFQ No | Outcome stratified by total Ca intake quartiles (top2 quartiles combined) | | X | X | X | | X | Ischemic stroke Total Ca(both)

A Nested case-control study

B This table is ordered alphabetically by study author

Table 50 Calcium and cardiovascular outcomes: Results of cohort studies

Author Year Study Name PMID | Age Range, Sex | Outcome (n/N; Incidence) | Followup Duration | Total Ca Intake, mg/day | No. of Cases | No. in Category | Adjusted OR | 95% CI | P for Trend | Study Quality
CVD Death
Men
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Men | CVD death (685/23,117; 0.030) | 8.9 y | 250, mean | 140 | 4623 | 1 | Reference | 0.95 | B
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Men | CVD death (685/23,117; 0.030) | 8.9 y | 363 | 141 | 4624 | 0.98 | 0.75, 1.30 | 0.95 | B
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Men | CVD death (685/23,117; 0.030) | 8.9 y | 449 | 135 | 4623 | 0.93 | 0.67, 1.29 | 0.95 | B
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Men | CVD death (685/23,117; 0.030) | 8.9 y | 536 | 135 | 4624 | 0.92 | 0.64, 1.32 | 0.95 | B
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Men | CVD death (685/23,117; 0.030) | 8.9 y | 665 | 134 | 4623 | 0.97 | 0.64, 1.48 | 0.95 | B
van der Vijver1992^105^ Dutch civil servants [1544755] | 40–65 y, Men | CVD death (nd/1340; ~0.27, age-adjusted) | 28 y | ≤585 | 31.9%, age- adjusted | 271 | 1.3 | 0.8, 1.9 | nd | B
van der Vijver1992^105^ Dutch civil servants [1544755] | 40–65 y, Men | CVD death (nd/1340; ~0.27, age-adjusted) | 28 y | 585–1245 | 26.7% | 798 | 1.1 | 0.8, 1.5 | nd | B
van der Vijver1992^105^ Dutch civil servants [1544755] | 40–65 y, Men | CVD death (nd/1340; ~0.27, age-adjusted) | 28 y | >1245 | 24.9% | 271 | 1 | Reference | nd | B
Women
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Women | CVD death (644/35,609; 0.018) | 8.9 y | 266, mean | 153 | 7121 | 1 | Reference | 0.14 | B
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Women | CVD death (644/35,609; 0.018) | 8.9 y | 379 | 156 | 7122 | 1.29 | 0.99, 1.67 | 0.14 | B
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Women | CVD death (644/35,609; 0.018) | 8.9 y | 462 | 136 | 7122 | 1.24 | 0.90, 1.69 | 0.14 | B
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Women | CVD death (644/35,609; 0.018) | 8.9 y | 545 | 98 | 7122 | 0.92 | 0.64, 1.34 | 0.14 | B
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Women | CVD death (644/35,609; 0.018) | 8.9 y | 667 | 101 | 7122 | 1.14 | 0.74, 1.74 | 0.14 | B
van der Vijver1992^105^ Dutch civil servants [1544755] | 40–65 y, Women | CVD death (nd/1265; ~0.14, age-adjusted) | 28 y | ≤445 | 14.6%, age- adjusted | 258 | 1.1 | 0.6, 2.0 | nd | B
van der Vijver1992^105^ Dutch civil servants [1544755] | 40–65 y, Women | CVD death (nd/1265; ~0.14, age-adjusted) | 28 y | 445–850 | 14.4% | 750 | 1.1 | 0.7, 1.7 | nd | B
van der Vijver1992^105^ Dutch civil servants [1544755] | 40–65 y, Women | CVD death (nd/1265; ~0.14, age-adjusted) | 28 y | >850 | 12.6% | 257 | 1 | Reference | nd | B
Cardiac Events, Total
Both Sexes
Umesawa 2008^106^ Japan PHC [18635855] | 40–59 y, Both | CHD (322/41,526; 0.0078) | 13 y | 233, median | 72 | ~8305 | 1 | Reference | NS | A
Umesawa 2008^106^ Japan PHC [18635855] | 40–59 y, Both | CHD (322/41,526; 0.0078) | 13 y | 344 | 72 | ~8305 | 1.18 | 0.83, 1.68 | NS | A
Umesawa 2008^106^ Japan PHC [18635855] | 40–59 y, Both | CHD (322/41,526; 0.0078) | 13 y | 439 | 56 | ~8305 | 0.91 | 0.60, 1.37 | NS | A
Umesawa 2008^106^ Japan PHC [18635855] | 40–59 y, Both | CHD (322/41,526; 0.0078) | 13 y | 603 | 58 | ~8305 | 1.08 | 0.71, 1.65 | NS | A
Umesawa 2008^106^ Japan PHC [18635855] | 40–59 y, Both | CHD (322/41,526; 0.0078) | 13 y | 753 | 64 | ~8305 | 0.93 | 0.58, 1.50 | NS | A
Marniemi 2005^48^ (Finland) [15955467] | 65–99 y, Both | AMI (130/755; 0.172) | 10 y | nd | nd | ~252 | 1 | Reference | nd | C
Marniemi 2005^48^ (Finland) [15955467] | 65–99 y, Both | AMI (130/755; 0.172) | 10 y | nd | nd | ~252 | 0.87 | 0.57, 1.37 | nd | C
Marniemi 2005^48^ (Finland) [15955467] | 65–99 y, Both | AMI (130/755; 0.172) | 10 y | nd | nd | ~252 | 1.14 | 0.70, 1.84 | nd | C
Men
Al-Delaimy 2003^107^ HPFS [12663277] | Mean (SD) 54 (9) y, Men | IHD, total (1458/39,800; 0.037) | 12 y | 523, mean | 300 | 7960 | 1 | Reference | 0.43 | A
Al-Delaimy 2003^107^ HPFS [12663277] | Mean (SD) 54 (9) y, Men | IHD, total (1458/39,800; 0.037) | 12 y | 670 | 296 | 7960 | 1.03 | 0.88, 1.22 | 0.43 | A
Al-Delaimy 2003^107^ HPFS [12663277] | Mean (SD) 54 (9) y, Men | IHD, total (1458/39,800; 0.037) | 12 y | 803 | 267 | 7960 | 0.92 | 0.78, 1.09 | 0.43 | A
Al-Delaimy 2003^107^ HPFS [12663277] | Mean (SD) 54 (9) y, Men | IHD, total (1458/39,800; 0.037) | 12 y | 995 | 299 | 7960 | 1.01 | 0.85, 1.19 | 0.43 | A
Al-Delaimy 2003^107^ HPFS [12663277] | Mean (SD) 54 (9) y, Men | IHD, total (1458/39,800; 0.037) | 12 y | 1377 | 296 | 7960 | 0.94 | 0.79, 1.11 | 0.43 | A
Cardiac Death Men
Al-Delaimy 2003^107^ HPFS [12663277] | Mean (SD) 54 (9) y, Men | IHD death (428/39,800; 0.011) | 12 y | 523, mean | 88 | 7960 | 1 | Reference | 0.72 | A
Al-Delaimy 2003^107^ HPFS [12663277] | Mean (SD) 54 (9) y, Men | IHD death (428/39,800; 0.011) | 12 y | 670 | 90 | 7960 | 1.17 | 0.87, 1.50 | 0.72 | A
Al-Delaimy 2003^107^ HPFS [12663277] | Mean (SD) 54 (9) y, Men | IHD death (428/39,800; 0.011) | 12 y | 803 | 70 | 7960 | 0.93 | 0.67, 1.29 | 0.72 | A
Al-Delaimy 2003^107^ HPFS [12663277] | Mean (SD) 54 (9) y, Men | IHD death (428/39,800; 0.011) | 12 y | 995 | 79 | 7960 | 1.06 | 0.77, 1.47 | 0.72 | A
Al-Delaimy 2003^107^ HPFS [12663277] | Mean (SD) 54 (9) y, Men | IHD death (428/39,800; 0.011) | 12 y | 1377 | 101 | 7960 | 1.10 | 0.79, 1.51 | 0.72 | A
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Men | CHD death (148/23,117; 0.0064) | 8.9 y | 250, mean | 37 | 4623 | 1 | Reference | 0.43 | A
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Men | CHD death (148/23,117; 0.0064) | 8.9 y | 363 | 26 | 4624 | 0.84 | 0.47, 1.50 | 0.43 | A
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Men | CHD death (148/23,117; 0.0064) | 8.9 y | 449 | 33 | 4623 | 1.20 | 0.62, 2.30 | 0.43 | A
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Men | CHD death (148/23,117; 0.0064) | 8.9 y | 536 | 32 | 4624 | 1.27 | 0.60, 2.68 | 0.43 | A
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Men | CHD death (148/23,117; 0.0064) | 8.9 y | 665 | 20 | 4623 | 0.92 | 0.37, 2.29 | 0.43 | A
van der Vijver1992^105^ Dutch civil servants 1544755 | 40–65 y, Men | CHD death (nd/1340; ~0.15, age-adjusted) | 28 y | ≤ 585 | 16.6%, age- adjusted | 271 | 0.9 | 0.6, 1.6 | nd | B
van der Vijver1992^105^ Dutch civil servants 1544755 | 40–65 y, Men | CHD death (nd/1340; ~0.15, age-adjusted) | 28 y | 585–1245 | 15.1% | 798 | 1.0 | 0.6, 1.5 | nd | B
van der Vijver1992^105^ Dutch civil servants 1544755 | 40–65 y, Men | CHD death (nd/1340; ~0.15, age-adjusted) | 28 y | >1245 | 14.5% | 271 | 1 | Reference | nd | B
Women
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Women | CHD death (116/35,609; 0.0033) | 8.9 y | 266, mean | 38 | 7121 | 1 | Reference | 0.50 | A
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Women | CHD death (116/35,609; 0.0033) | 8.9 y | 379 | 21 | 7122 | 0.88 | 0.48, 1.62 | 0.50 | A
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Women | CHD death (116/35,609; 0.0033) | 8.9 y | 462 | 25 | 7122 | 1.28 | 0.62, 2.61 | 0.50 | A
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Women | CHD death (116/35,609; 0.0033) | 8.9 y | 545 | 17 | 7122 | 0.84 | 0.35, 2.02 | 0.50 | A
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Women | CHD death (116/35,609; 0.0033) | 8.9 y | 667 | 15 | 7122 | 0.87 | 0.31, 2.45 | 0.50 | A
Bostick 1999^110^ Iowa WHS [9921960] | 55–69 y, Women | IHD death (387/34,486; 0.011) | 8 y | <696 | 127 | ~8621 | 1 | Reference | 0.09 | B
Bostick 1999^110^ Iowa WHS [9921960] | 55–69 y, Women | IHD death (387/34,486; 0.011) | 8 y | 696–1051 | 84 | ~8621 | 0.62 | 0.45, 0.85^*^ | 0.09 | B
Bostick 1999^110^ Iowa WHS [9921960] | 55–69 y, Women | IHD death (387/34,486; 0.011) | 8 y | 1052–1425 | 94 | ~8621 | 0.75 | 0.55, 1.03 | 0.09 | B
Bostick 1999^110^ Iowa WHS [9921960] | 55–69 y, Women | IHD death (387/34,486; 0.011) | 8 y | >1425 | 82 | ~8621 | 0.67 | 0.47, 0.94^*^ | 0.09 | B
van der Vijver1992^105^ Dutch civil servants [1544755] | 40–65 y, Women | CHD death (nd/1265; ~0.06, age-adjusted) | 28 y | ≤445 | 6.2%, age- adjusted | 258 | 1.1 | 0.5, 2.5 | nd | B
van der Vijver1992^105^ Dutch civil servants [1544755] | 40–65 y, Women | CHD death (nd/1265; ~0.06, age-adjusted) | 28 y | 445–850 | 6.3% | 750 | 1.2 | 0.6, 2.3 | nd | B
van der Vijver1992^105^ Dutch civil servants [1544755] | 40–65 y, Women | CHD death (nd/1265; ~0.06, age-adjusted) | 28 y | >850 | 4.4% | 257 | 1 | Reference | nd | B
Cardiac Event, Nonfatal
Men
Al-Delaimy 2003^107^ HPFS [12663277] | Mean (SD) 54 (9) y, Men | Nonfatal MI (1030/39,800; 0.026) | 12 y | 523, mean | 212 | 7960 | 1 | Reference | 0.43 | A
Al-Delaimy 2003^107^ HPFS [12663277] | Mean (SD) 54 (9) y, Men | Nonfatal MI (1030/39,800; 0.026) | 12 y | 670 | 206 | 7960 | 1.01 | 0.83, 1.23 | 0.43 | A
Al-Delaimy 2003^107^ HPFS [12663277] | Mean (SD) 54 (9) y, Men | Nonfatal MI (1030/39,800; 0.026) | 12 y | 803 | 197 | 7960 | 0.96 | 0.78, 1.17 | 0.43 | A
Al-Delaimy 2003^107^ HPFS [12663277] | Mean (SD) 54 (9) y, Men | Nonfatal MI (1030/39,800; 0.026) | 12 y | 995 | 220 | 7960 | 1.04 | 0.85, 1.28 | 0.43 | A
Al-Delaimy 2003^107^ HPFS [12663277] | Mean (SD) 54 (9) y, Men | Nonfatal MI (1030/39,800; 0.026) | 12 y | 1377 | 195 | 7960 | 0.92 | 0.74, 1.14 | 0.43 | A
Stroke
Both Sexes
Umesawa 2008^106^ Japan PHC [18635855] | 40–59 y, Both | Stroke, Total (1321/41,526; 0.032) | 13 y | 233, median | 314 | ~8305 | 1 | Reference | 0.02 | A
Umesawa 2008^106^ Japan PHC [18635855] | 40–59 y, Both | Stroke, Total (1321/41,526; 0.032) | 13 y | 344 | 257 | ~8305 | 0.94 | 0.79, 1.13 | 0.02 | A
Umesawa 2008^106^ Japan PHC [18635855] | 40–59 y, Both | Stroke, Total (1321/41,526; 0.032) | 13 y | 439 | 252 | ~8305 | 0.79 | 0.65, 0.97^*^ | 0.02 | A
Umesawa 2008^106^ Japan PHC [18635855] | 40–59 y, Both | Stroke, Total (1321/41,526; 0.032) | 13 y | 603 | 247 | ~8305 | 0.78 | 0.63, 0.96^*^ | 0.02 | A
Umesawa 2008^106^ Japan PHC [18635855] | 40–59 y, Both | Stroke, Total (1321/41,526; 0.032) | 13 y | 753 | 251 | ~8305 | 0.71 | 0.56, 0.89^*^ | 0.02 | A
Weng 2008^108^ CVD—FACTS [18988909] | ≥40 y Both | Stroke, Ischemic (132/1772; 0.074) | 10.6 y | <451 | nd | 443 | 1.52 | 0.98, 2.35 | 0.03 | B
Weng 2008^108^ CVD—FACTS [18988909] | ≥40 y Both | Stroke, Ischemic (132/1772; 0.074) | 10.6 y | 451–591 | nd | 443 | 1.49 | 0.99, 2.24 | 0.03 | B
Weng 2008^108^ CVD—FACTS [18988909] | ≥40 y Both | Stroke, Ischemic (132/1772; 0.074) | 10.6 y | >591 | nd | 886 | 1 | Reference | 0.03 | B
Marniemi 2005^48^ (Finland) [15955467] | 65–99 y, Both | Stroke, Total(70/755; 0.093) | 10 y | nd | nd | ~252 | 1 | Reference | nd | C
Marniemi 2005^48^ (Finland) [15955467] | 65–99 y, Both | Stroke, Total(70/755; 0.093) | 10 y | nd | nd | ~252 | 0.981 | 0.53, 1.81 | nd | C
Marniemi 2005^48^ (Finland) [15955467] | 65–99 y, Both | Stroke, Total(70/755; 0.093) | 10 y | nd | nd | ~252 | 1.34 | 0.70, 2.55 | nd | C
Men
Ascherio 1998^109^ HPFS [9743511] | 40–75 y, Men | Stroke, Total (328/43,738; 0.0075) | 8 y | 500, median | 75 | ~8748 | 1 | Reference | 0.10 | A
Ascherio 1998^109^ HPFS [9743511] | 40–75 y, Men | Stroke, Total (328/43,738; 0.0075) | 8 y | 700 | 69 | ~8748 | 0.95 | 0.68, 1.32 | 0.10 | A
Ascherio 1998^109^ HPFS [9743511] | 40–75 y, Men | Stroke, Total (328/43,738; 0.0075) | 8 y | 800 | 51 | ~8748 | 0.72 | 0.50, 1.03 | 0.10 | A
Ascherio 1998^109^ HPFS [9743511] | 40–75 y, Men | Stroke, Total (328/43,738; 0.0075) | 8 y | 1000 | 63 | ~8748 | 0.84 | 0.60, 1.19 | 0.10 | A
Ascherio 1998^109^ HPFS [9743511] | 40–75 y, Men | Stroke, Total (328/43,738; 0.0075) | 8 y | 1400 | 70 | ~8748 | 0.88 | 0.63, 1.23 | 0.10 | A
Larsson 2008^112^ ATBC [18332289] | 50–69 y, Men | Cerebral infarction (2702/26,556; 0.102) | 13.6 y | 876, median | 518 | ~5311 | 1 | Reference | 0.09 | C
Larsson 2008^112^ ATBC [18332289] | 50–69 y, Men | Cerebral infarction (2702/26,556; 0.102) | 13.6 y | 1178 | 541 | ~5311 | 1.08 | 0.95, 1.22 | 0.09 | C
Larsson 2008^112^ ATBC [18332289] | 50–69 y, Men | Cerebral infarction (2702/26,556; 0.102) | 13.6 y | 1379 | 542 | ~5311 | 1.09 | 0.96, 1.23 | 0.09 | C
Larsson 2008^112^ ATBC [18332289] | 50–69 y, Men | Cerebral infarction (2702/26,556; 0.102) | 13.6 y | 1581 | 546 | ~5311 | 1.11 | 0.98, 1.26 | 0.09 | C
Larsson 2008^112^ ATBC [18332289] | 50–69 y, Men | Cerebral infarction (2702/26,556; 0.102) | 13.6 y | 1916 | 555 | ~5311 | 1.10 | 0.98, 1.26 | 0.09 | C
Women
Iso 1999^111^ NHS [10471422] | 32–57 y, Women | Stroke, Total (690/85,764; 0.0080) | 14 y | 395, median | 165 | ~17153 | 1 | Reference | NS | A
Iso 1999^111^ NHS [10471422] | 32–57 y, Women | Stroke, Total (690/85,764; 0.0080) | 14 y | 645 | 132 | ~17153 | 0.79 | 0.63, 1.00^*^ | NS | A
Iso 1999^111^ NHS [10471422] | 32–57 y, Women | Stroke, Total (690/85,764; 0.0080) | 14 y | 675 | 117 | ~17153 | 0.71 | 0.56, 0.90^*^ | NS | A
Iso 1999^111^ NHS [10471422] | 32–57 y, Women | Stroke, Total (690/85,764; 0.0080) | 14 y | 837 | 142 | ~17153 | 0.87 | 0.70, 1.09 | NS | A
Iso 1999^111^ NHS [10471422] | 32–57 y, Women | Stroke, Total (690/85,764; 0.0080) | 14 y | 1145 | 134 | ~17153 | 0.83 | 0.66, 1.04 | NS | A
Stroke, Fatal
Men
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Men | Stroke death (322/23,117; 0.014) | 8.9 y | 250, mean | 61 | 4623 | 1 | Reference | 0.95 | A
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Men | Stroke death (322/23,117; 0.014) | 8.9 y | 363 | 76 | 4624 | 1.14 | 0.76, 1.70 | 0.95 | A
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Men | Stroke death (322/23,117; 0.014) | 8.9 y | 449 | 69 | 4623 | 0.90 | 0.56, 1.45 | 0.95 | A
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Men | Stroke death (322/23,117; 0.014) | 8.9 y | 536 | 59 | 4624 | 0.69 | 0.40, 1.18 | 0.95 | A
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Men | Stroke death (322/23,117; 0.014) | 8.9 y | 665 | 57 | 4623 | 0.68 | 0.37, 1.26 | 0.95 | A
Ross 1997^113,A^ (China) [9236416] | 45–64 y, Men | Stroke death (245/18,244;0.013) [245 cases vs. 1225 controls] | 12 y | nd | 103 | 460 controls | 1 | Reference | NS | C
Ross 1997^113,A^ (China) [9236416] | 45–64 y, Men | Stroke death (245/18,244;0.013) [245 cases vs. 1225 controls] | 12 y | nd | 68 | 369 controls | 0.8 | 0.6, 1.6 | NS | C
Ross 1997^113,A^ (China) [9236416] | 45–64 y, Men | Stroke death (245/18,244;0.013) [245 cases vs. 1225 controls] | 12 y | nd | 74 | 396 controls | 1.0 | 0.8, 1.4 | NS | C
Women
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Women | Stroke death (322/35,609; 0.0090) | 8.9 y | 266, mean | 70 | 7121 | 1 | Reference | 0.50 | A
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Women | Stroke death (322/35,609; 0.0090) | 8.9 y | 379 | 82 | 7122 | 1.38 | 0.95, 2.01 | 0.50 | A
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Women | Stroke death (322/35,609; 0.0090) | 8.9 y | 462 | 73 | 7122 | 1.24 | 0.79, 1.95 | 0.50 | A
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Women | Stroke death (322/35,609; 0.0090) | 8.9 y | 545 | 42 | 7122 | 0.69 | 0.40, 1.18 | 0.50 | A
Umesawa 2006^104^ Japan CC [16339476] | 40–79 y, Women | Stroke death (322/35,609; 0.0090) | 8.9 y | 667 | 55 | 7122 | 0.94 | 0.51, 1.72 | 0.50 | A

* Statistically significant (P<0.05)

A Case-control study from prospective, longitudinal cohort.

Figure 11 Cardiovascular outcomes risk stratified by calcium intake

Figure 12 Stroke risk stratified by calcium intake

Cardiovascular death

Two longitudinal cohort studies analyzed risk of cardiovascular death (death from cardiac or cerebrovascular events), separately in men and women, according to quintiles.

In the Japan Collaborative Cohort (Japan CC),104 about 23,000 men aged 40 to 79 years without a history of cardiovascular disease were followed for 8.9 years; 3 percent died of a cardiovascular event. Men within the calcium quintiles had mean calcium intakes that ranged from 250 to 665 mg/day. No significant association was found between calcium quintile and cardiovascular death risk. In a study of Dutch civil servants (and spouses),105 1340 men aged 40 to 65 years (regardless of cardiovascular history) were followed for 28 years. About 27 percent (age-adjusted) had a cardiovascular death. The calcium intake quintiles ranged from less than 585 mg/day to more than 1245 mg/day. No significant associations were found between calcium intake and risk of cardiovascular death; however, men in the lowest quintile (≤585 mg/day) had an adjusted odds ratio of cardiovascular death of 1.3 (95 percent CI 0.8, 1.9) compared to those in the highest quintile. Both studies had methodological quality B. The Japanese study did not define cardiovascular mortality and the Dutch study did not report a complete analysis of the calcium intake quintiles.

In the Japan CC, about 35,600 women aged 40 to 79 years without a history of cardiovascular disease were followed for 8.9 years; 1.8 percent died of a cardiovascular event. Women within the calcium quintiles had mean calcium intakes that ranged from 266 to 667 mg/day. No significant trend across quintiles or associations among quintiles was found for risk of cardiovascular death. However, women in the lowest quintile had about 25 to 30 percent lower risks of cardiovascular death than women in the next two higher quintiles. In the Dutch civil servants study, 1265 women were followed for 28 years. About 14 percent had a cardiovascular death. The calcium intake quintiles ranged from less than 445 mg/day to more than 850 mg/day. No significant associations were found between calcium intake and risk of cardiovascular death.

Cardiac events, total

Three longitudinal cohort studies analyzed combined fatal and nonfatal cardiac events, including coronary heart disease, acute myocardial infarction, and ischemic heart disease; two combined both sexes, one included only men.

In the Japan Public Health Center (Japan PHC) study (methodological quality A),106 about 41,500 people aged 40 to 59 years, without cardiovascular disease, were followed for 13 years; 0.8 percent had cardiac events. People within the calcium intake quintiles had median calcium intakes that ranged from 233 to 753 mg/day. No association was found between calcium intake and risk of coronary heart disease events. In a small Finnish longitudinal study,48 755 people aged 65 to 99 years, regardless of cardiovascular history were followed for 10 years; 17 percent had a cardiac event. No significant association was found between tertiles of calcium intake and all acute myocardial infarctions. This methodological quality C study did not report relevant data including information on the calcium intake within the tertiles.

In the Health Professionals Follow-up Study (HPFS),107 about 39,000 men with a mean age of 54 years, without cardiovascular disease were followed for 12 years; 3.7 percent had an ischemic heart disease event. The study was of methodological quality A. Men within the calcium quintiles had mean calcium intakes that ranged from 523 to 1377 mg/day. No significant association was found between calcium intake and risk of cardiac events.

Cardiac death

Four longitudinal cohort studies analyzed death from cardiac events, separately in men (3 studies) and women (3 studies).

In the three studies of men, all found no significant association between calcium intake and cardiac death. All three studies are described above. In HPFS 1.1 percent of men died of a cardiac event during 12 years of followup.107 In the Japan CC study 0.6 percent of men died of a cardiac event during 9 years of followup (methodological quality A for this outcome).104 In the Dutch civil servants study about 15 percent (age-adjusted) died of a cardiac event during 28 years of followup.105

Three studies analyzed cardiac death in women. In two studies, both described above, there was no significant association between calcium intake and cardiac death. In the Japan CC study 0.3 percent of women died of a cardiac event during 9 years of followup.104 In the Dutch civil servants study about 6 percent (age-adjusted) died of a cardiac event during 28 years of followup.105 The Iowa Women’s Health Study (Iowa WHS) analyzed about 34,500 white women, aged 55 to 69 years, without ischemic heart disease. During 8 years of followup, 1.1 percent died of a cardiac event. However, the study was of methodological quality B for this outcome because the outcome was not fully ascertained. The calcium intake quartiles ranged from less than 696 mg/day to more than 1425 mg/day. There was a suggestion of an association between lower calcium intake and higher risk of cardiac death, with a P value of 0.09 for the trend across quartiles and statistically significant adjusted relative risks of cardiac death for women with calcium intakes above 696 mg/day of 0.62 to 0.75 (compared to the lowest quartile).

Cardiac events, nonfatal

Only the HPFS, described above, analyzed nonfatal cardiac events (methodological quality A).107 During 12 years of followup 2.6 percent of almost 40,000 men had nonfatal myocardial infarctions. No significant association was found between calcium intake and nonfatal cardiac events.

Stroke, total

Six longitudinal cohort studies analyzed combined fatal and nonfatal strokes, in either both sexes combined, or men and women separately.

In the Japan PHC study, described above (cardiac events, total), 3 percent of people suffered strokes during 13 years of followup (methodological quality A).106 The study found a significant association between baseline calcium intake and risk of stroke. The risk of stroke was progressively lower in progressively higher quintiles of calcium intake. People with a median calcium intake of 439 mg/day (middle quintile) had a statistically significant adjusted hazard ratio (HR) of 0.79 compared to those with a median calcium intake of 233 mg/day. Those in higher quintiles had lower HRs; across quintiles, the trend had a P value of 0.02. As is evident from the median calcium intake levels within the quintiles, the middle-aged Japanese in this study had considerably lower average calcium intake than in most other studies (particularly those performed in the US). Compared to similar studies evaluated here, the calcium intake was approximately half of that in the HPFS or Iowa WHS. The CVD-FACTS study, performed in men and women at least 40 years old in Taiwan, evaluated ischemic strokes.108 After a mean followup of 10.6 years, 7.4 percent of the cohort had an ischemic stroke. The B quality study divided the cohort into tertiles. Similar to the Japanese study, the typical calcium intake was relatively low by Western standards (the average dietary calcium intake was approximately 520 mg/day). Those in the lower two tertiles had about a 50 percent increased risk of ischemic stroke than those in the highest tertile (>591 mg/day). While the adjusted OR for each tertile were not quite statistically significant (1.52 [95 percent CI 0.98–2.35] for lowest tertile; 1.49 [95 percent CI 0.99–2.24] for middle tertile; compared to highest tertile), the trend across tertiles had a P value of 0.03. The third study of combined men and women, of older Finns (described above under Cardiac events, total), found no significant association with stroke among 755 people followed for 10 years (stroke incidence 9.3 percent; methodological quality C).48

Both studies of men alone suggest trends across quintiles of calcium intake and stroke risk; however, the associations were in opposite directions. The HPFS, described above (cardiac events, total; methodological quality A) had a stroke incidence of 0.75 percent during 8 years of followup. Men in higher quintiles of calcium intake had generally lower adjusted relative risks (RR) of stroke compared to the lowest quintile (median calcium intake 500 mg/day); though none of the RRs was statistically significant and the P value for the trend across quintiles was 0.10. Notably, the RR of stroke for men in the middle quintile (median calcium intake 800 mg/day) was 0.72 (95 percent CI 0.50, 1.03); though the RRs for men in higher quintiles were closer to 1 with wider 95 percent confidence intervals. In the Alpha-Tocopherol, Beta-Carotene Cancer Prevention (ATBC) Study, performed in southern Finland, about 26,500 men aged 50 to 69 years without a history of stroke were followed for almost 14 years; 10 percent suffered a stroke. The study was of methodological quality C because there was large misclassification of stroke outcomes in a sample of subjects (5–21 percent). Men in the lowest quintile of calcium intake (median 876 mg/day) had the lowest adjusted RR for cerebral infarction. Men in all higher quintiles (medians ranging from 1178 to 1916 mg/day) all had RR of about 1.10 that were near statistical significance (e.g., 95 percent CI for highest quartile was 0.98, 1.26). The P value of the trend of association across quintiles was 0.09.

One study evaluated total strokes in women alone. The Nurses Health Study (NHS) evaluated about 86,000 women aged 32 to 57 years with no history of cardiovascular disease. The study was rated methodological quality A. During 14 years of followup 0.8 percent of women suffered a stroke. The women in the four quintiles above the lowest quintile (who had a median calcium intake of 395 mg/day) all had similar adjusted RR of stroke (0.71–0.87); the RRs of those women in the second and third quintiles were statistically significant. However, the trend of associations across quintiles was not statistically significant.

Stroke death

One longitudinal cohort study (with subanalyses in men and women separately) and one nested case-control study (in men) evaluated fatal strokes.

Both studies of men found no significant association between calcium intake and risk of stroke death. In the Japan CC study (described above, methodological quality A for this outcome) 1.4 percent of men died of stroke during 9 years of followup. The second study was a nested case-control study performed in China. In a prospective cohort of about 18,000 men aged 45 to 64 years, regardless of cardiovascular history, 245 died of stroke (1.3 percent) during 12 years of followup. These cases were matched with 1225 controls. The remaining 17,000 men were omitted from the analysis. The study also did not report data on the calcium intake within the tertiles. The methodological quality was C.

In the Japan CC study, 0.9 percent of women died of stroke. The study also found no consistent association between calcium intake and stroke death.

Findings per calcium intake level

Among the outcomes for which studies had either statistically significant associations or suggestions of associations between calcium intake and cardiovascular events, the following findings of calcium intake level were reported.

Regarding the risk of overall cardiovascular mortality, one of two studies in women (Japan CC) found a suggestion that higher calcium intake may be associated with increased risk of cardiovascular death. The association can be seen for quintiles 2 to 4, where women in the lowest quintile had a median calcium intake of 266 mg/day and those in the second quintile had a median calcium intake of 379 mg/day.

Regarding the risk of cardiac mortality, one of three studies in women (Iowa WHS) found that women in the lowest quartile of calcium intake, below 696 mg/day, had the highest risk of cardiac mortality.

Regarding the risk of stroke, among studies of both sexes combined, two (Japan PHC and the Taiwanese CVD-FACTS) of three studies found a statistically significant association between lower calcium intake and higher risk of stroke. In Japan PHC, those in the third to fifth quintiles, with median calcium intakes of 439 mg/day or higher, had lower risks than those in the lowest quintile. Those in the second quintile had a median calcium intake of 344 mg/day and those in the lowest quintile 233 mg/day. In CVD-FACTS, those in the two tertiles with calcium intake below 591 mg/day had about a 50 percent increased risk of stroke compared to those with higher calcium intake. The two studies restricted to men had opposite findings. The HPFS found lower risks of stroke among men in the third to fifth quintiles of calcium intake (median 800 mg/day or higher) compared to the lowest quintile (median 500 mg/day). Those in the second quintile had a median calcium intake of 700 mg/day. In contrast, the ATBC study in Finland found somewhat higher risks of stroke (RR~1.1) in all quintiles above the lowest quintile. The median calcium intakes in the first and second quintiles were 876 and 1178 mg/day, respectively. The one study of women (NHS) had lower risks of stroke in all quintiles above the lowest quintile. The median calcium intakes in the first and second quintiles were 395 and 645 mg/day, respectively.

Findings per age and sex

The majority of studies (and the large majority of individuals) included mostly people between the ages of about 40 and 70 years. The youngest individuals included were 32 year old women in the NHS. Apparently very few individuals were over the age of 70 years. Only a small Finnish study (Marniemi 2005^48^) restricted the study cohort to only older adults (65 years and older). This study found no significant associations between calcium intake and cardiovascular events. No study reported a subgroup analysis based on age. The reported data do not allow further conclusions based on age.

Almost all studies or analyses separately evaluated men and women. The findings that could be interpreted as an association between calcium intake and cardiovascular risk were mostly found in women (low calcium intake being associated with increased risk of cardiac death (in one of three studies) and stroke (in a single study), but with lowered risk of overall cardiovascular death (in one of two studies). The only potential associations between calcium intake and cardiovascular events in men were found for stroke; however, the two studies had opposite findings about the direction of the association.

Findings by life stage

- 0–6 mo Not reviewed
- 7 mo–2 y Not reviewed
- 3–8 y Not reviewed
- 9–18 y Not reviewed
- 19–50 y Overall, the studies included relatively few people in this life stage. All were at least 32 years old, and most were at least 40 to 45 years old. However, the one study of stroke in women was conducted in women who were mostly in this life stage. Those in the lowest quintile of the NHS appear to have had higher risks of stroke than those women with greater calcium intake.
- 51–70 y The majority of evidence regards people in this life stage. Overall, the majority of analyses found no significant association between calcium intake and most cardiovascular events. Only for stroke did at least two studies find significant associations between calcium intake and the outcome. In two Asian studies, where the average dietary calcium intake was about half that in the US and which also included people in the younger life stage, stroke risk was progressively higher in lower quantiles (maximum quantiles were median of 753 mg/day and >591 mg/day). For studies of people within this life stage, other significant associations were found in one of three studies of cardiac death in women (calcium intake below 696 mg/day was associated with increased risk) and in one of two studies of cardiovascular death in women (calcium intake above about 300 mg/day may be associated with increased risk).
- ≥71 y Few studies included people in this life stage. The one study of people in this life stage found no association between calcium intake and cardiac events or stroke in a relatively small, quality C study.
- Postmenopause Only the Iowa WHS included primarily postmenopausal women. In their analysis, calcium intake below 696 mg/day was associated with increased risk of ischemic heart disease death.
- Pregnant & lactating women Not reviewed

### Calcium and Body Weight

We searched for systematic reviews and primary studies that evaluated associations between calcium intake or body stores and incidence of overweight or obesity; no such studies were found. For the outcome weight change (in kilograms or body mass index units), we included only randomized controlled trials. The EPC and the TEP agreed that the limited resources would not be expended on reviewing observational studies for the surrogate outcome body weight (where overweight or obesity are considered to be the clinical outcomes). We included only studies of adults. Studies of weight gain in children are included in the “Growth” section.

Synopsis

No studies evaluated the association of calcium intake and incidence of overweight or obesity. We identified three systematic reviews that evaluated RCTs of calcium intake and changes in body weight. Eight additional trials not identified by these systematic reviews met eligibility criteria for this report and are summarized together with the systematic reviews. Altogether, 49 trials have been identified by the previous and current systematic reviews. Because the systematic reviews all used somewhat different eligibility criteria, they included overlapping groups of trials. No one or two systematic reviews captured most of the relevant trials; therefore, all systematic reviews are included here.

The three systematic reviews performed separate analyses for calcium supplementation and dairy product intake. Only one of the systematic reviews separately analyzed studies of people on isocaloric diets (where weight loss was not a goal) and studies of people on energy-restricted diets. Overall, 24 included trials investigated calcium supplementation and 15 investigated dairy product intake; 29 trials had isocaloric background diets and 13 evaluated calcium supplementation in the setting of an energy-restricted (weight loss) diets. Although there was not complete agreement among the systematic reviews, overall, the trials in the systematic review do not support an effect of calcium (or dairy) supplementation on body weight. No systematic review analyzed effects of calcium supplementation based on life stage or calcium dose.

Seven of the eight additional trials investigated calcium supplements in the setting of isocaloric diets; two of the trials investigated calcium supplements in overweight people on energy-restricted diets. All these trials found no significant effect of calcium supplementation on body weight.

Detailed presentation

(Tables 51, 52, & 53)

Table 51 Systematic reviews of calcium supplementation and weight

Author Year [PMID] | Lanou 2008^114^ [18454813]
Design (Search Years) | Randomized controlled trials (1966–2007)
Population | All, generally healthy (adults and children, only studies of adults included here)
Intervention and Comparator | Calcium supplements or dairy intake versus no supplement or low calcium intake
Results | 29 trials^A^ No energy restriction Calcium supplement: 8/9 trials no significant effect. 1 found significantly more weight loss on calcium supplement. Dairy supplementation: 8/10 trials no significant effect. 2 found significantly more weight gain among those on dairy Energy restriction Calcium supplement: 4/5 trials no significant effect. 1 found significantly more weight loss with calcium. Dairy supplementation: 3/6 trials significantly more weight loss on high calcium intake All 4 trials with significant differences were by same study investigators
Comments
AMSTAR
A priori design? | Yes | Study quality assessment performed? | No
Two independent reviewers? | nd | Study quality appropriately used in analysis? | NA
Comprehensive literature search? | Yes | Appropriate statistical synthesis? | None
All publication types and languages included? | No | Publication bias assessed? | No
Included and excluded studies listed? | No | Conflicts of interest stated? | No
Study characteristics provided? | | Only published trials. Excluded studies not enumerated or listed.
Author Year [PMID] | Trowman 2006^115^ [16768823]
Design (Search Years) | Randomized controlled trials (1800^B^/2002–2004)
Population | Nonpregnant, nonlactating,≥18 y
Intervention and Comparator | Calcium supplements or dairy intake versus no supplement or low calcium intake
Results | 13 trials
Results | Calcium supplement | WMD = −1.79 (−3.04, −0.55)^C^, statistically homogeneous
Results | Dairy supplementation | WMD = +0.85 (−4.39, +6.08), statistically heterogeneous
Results | ANCOVA, adjusting for baseline weight:
Results | Calcium | Effect = −0.41 (−1.07, +0.25) kg
Results | Dairy | Effect = +0.23 (−2.88, +3.34) kg
Comments | Apparent difference in effect of calcium supplement trials may be due to significant differences (in aggregate) in baseline weights of two arms across studies (intervention arm participants were significantly lighter at baseline).
AMSTAR
A priori design? | Yes | Study quality assessment performed? | No
Two independent reviewers? | nd | Study quality appropriately used in analysis? | NA
Comprehensive literature search? | Yes | Appropriate statistical synthesis? | Debatable
All publication types and languages included? | Yes (implied) | Publication bias assessed? | Yes
Included and excluded studies listed? | No | Conflicts of interest stated? | Yes
Study characteristics provided? | Yes | Excluded studies not enumerated or listed. Used WMD instead of net difference, then needed to perform an ANCOVA to adjust for baseline differences
Author Year [PMID] | Barr 2003^116^ [12514301]
Design (Search Years) | Randomized controlled trials (1966–2001)
Population | All, generally healthy (adults and children, only studies of adults included here)
Intervention and Comparator | Calcium supplement or dietary calcium versus no supplement or usual calcium intake (see Comment)
Results | 8 trials Calcium supplement 7/8 trials found no significant effect
Comments | 6 dairy supplementation trials reviewed. Not included here. These represent a subset of the dairy trials reviewed by Lanou 2008^114^
AMSTAR
A priori design? | Yes | Study quality assessment performed? | No
Two independent reviewers? | nd | Study quality appropriately used in analysis? | NA
Comprehensive literature search? | Yes | Appropriate statistical synthesis? | None
All publication types and languages included? | No | Publication bias assessed? | No
Included and excluded studies listed? | No | Conflicts of interest stated? | No
Study characteristics provided? | Yes | Studies published in English only. Excluded studies not enumerated or listed.

WMD, weighted mean difference

A The systematic review included the Women’s Health Initiative (WHI) trial of vitamin D + calcium supplementation. This trial is omitted here and is discussed separately in the vitamin D + calcium and body weight section.

B Cochrane Library Database of Controlled Trials

C Numbers in parentheses are 95% confidence intervals

Table 52 Calcium and weight: Characteristics of RCTs

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Yamamoto 1995^117^ TOHP US (various) [7795837] | - Health status; - Mean age (range), y; - Male (%) | Healthy 43 (30–54) 69 | Ca 970 mg/d | Ca carbonate vs placebo | Eligibility for randomization required consumption of at least two-thirds of 6 wks of supplement placebo dosing. During the study, pill counts averaged 95% (with three-fourths taking at least 95% of their supplements).
Van Beresteyn 1986^118^ Netherlands (52°N) [3788835] | - Health status; - Mean age (range/SD), y; - Male (%) | Healthy 21 (20–23) 0 | nd | Ca carbonate vs placebo | nd
Cifuentes 2004^119^ New Brunswick, NJ (40°N) [15213038] | - Health status; - Mean age (range), y; - Male (%) | Overweight, post-menopause 61 (52–75) 0 | nd | Ca supplement vs placebo | nd | Factorial design with weight loss and maintenance diets
Ghadirian 1995^120^ Montreal, Canada (46°N) [7493659] | - Health status; - Mean age (range), y; - Male (%) | Healthy, post-menopause ~80 (~ ≥50) 0 | Ca 776 mg/d | Dairy vs dairy free intake | Non-compliant and those who provided incomplete data were excluded.
Aloia 1995^121^ Mineola, NY (41°N) [7892882] | - Health status; - Mean age (SD), y; - Male (%) | Healthy, post-menopause 53 (0.6) 0 | nd | Ca supplement vs placebo (Vit D in both groups) | nd
Thomsen 1987^122^ Copenhagen, Denmark (55°N) [3307307] | - Health status; - Mean age; - (range/SD), y; - Male (%) | Healthy, post-menopause nd 0 | nd | Combination Ca lactate-gluconate & Ca carbonate vs placebo | nd
Bortolotti 2008^124^ Lausanne, Switzerland (47°N) [18842771] | - Health status; - Mean age (SE), y; - Male (%) | Healthy 22 (1.2) 30 | Ca 586 (137 SE) mg/d, all <800 mg/d | Ca phosphate vs placebo | Measured but not reported | Crossover study (5 wk with 10 wk washout), 1° outcomes were metabolic
Kabrnova-Hlavata 2008^123^ Lausanne, Czech Rep (50°N) [17552880] | - Health status; - Mean age (SD), y; - Male (%); - Male (%) | Overweight, healthy 49 (12) 0 0 | nd | Ca carbonate vs “lactoval” vs placebo | nd (a dietitian checked that subjects took tablets) | Energy restriction

Table 53 Calcium and weight: Results of RCTs

Author Year Study Name [PMID] | Age Range, Sex | Outcome | 1°/2° | Mean Followup | Interventions, Daily Dose | No.Analyzed | Unit | Baseline | Change | Change 95% CI | Net Diff | Net Diff 95% CI | P Btw | Study Quality
Isocaloric
Yamamoto 1995^117^ TOHP [7795837] | 30–54 y, Both | BMI | 2° | 6 mo | Ca carbonate 1000 mg | 217 | Kg/m^2^ | 27.4 | +0.07 | −0.05, 0.19 | −0.05^A^ | −0.23, 0.13^B^ | NS | A
Yamamoto 1995^117^ TOHP [7795837] | 30–54 y, Both | BMI | 2° | 6 mo | Placebo | 218 | | 27.0 | +0.12 | −0.02, 0.26 | | | | A
van Beresteyn 1986^118^ Netherlands [3788835] | 20–23 y, Women | Weight | 2° | 6 wk | Ca carbonate 1500 mg | 29 | Kg | 61.8 | −0.3 | −2.7, 2.1^B^ | −0.8 | −4.3, 2.7^B^ | NS | B
van Beresteyn 1986^118^ Netherlands [3788835] | 20–23 y, Women | Weight | 2° | 6 wk | Placebo | 29 | | 62.5 | +0.5 | −2.0, 3.0^B^ | | | | B
van Beresteyn 1986^118^ Netherlands [3788835] | 20–23 y, Women | BMI | 2° | | Ca | 29 | Kg/m^2^ | 20.8 | −0.1 | −0.8, 0.6^B^ | −0.2 | −1.2, 0.8^B^ | NS
van Beresteyn 1986^118^ Netherlands [3788835] | 20–23 y, Women | BMI | 2° | | Placebo | 29 | | 21.0 | +0.1 | −0.6, 0.8^B^
Cifuentes 2004^119^ New Jersey [15213038] | 52–75 y, Women | Weight | 1° | 6 wk | Ca citrate 1200 mg | 10 | Kg | 70.9 | 0 | −3.3, 3.3^B^ | −0.4^C^ | −5.5, 4.7^B^ | NS | B
Cifuentes 2004^119^ New Jersey [15213038] | 52–75 y, Women | Weight | 1° | 6 wk | Ca citrate 400 mg | 15 | | 68.0 | +0.4 | −3.4, 4.2^B^ | | | | B
Ghadirian 1995^120^ Canada [7493659] | ~>=50 y, Women | Weight | 2° | 1 mo | Dairy intake (1242 mg Ca) | 81 | Kg | 59.84 | +0.10 | −2.4, 2.6^B^ | +0.5 | −3.7, 4.7^B^ | NS | C
Ghadirian 1995^120^ Canada [7493659] | ~>=50 y, Women | Weight | 2° | 1 mo | Nondairy intake (377 mg) | 77 | | 59.65 | −0.40 | −3.8, 3.0^B^ | | | | C
Aloia 1995^121^ New York [7892882] | Mean (SD) 53 (0.6) y, Women | Weight | 2° | 2.9 y | Ca 1700 mg^D^ + Vit D 400 IU | 36 | Kg/y | 65.8 | +0.1 | nd | 0 | nd | NS | C
Aloia 1995^121^ New York [7892882] | Mean (SD) 53 (0.6) y, Women | Weight | 2° | 2.9 y | Vit D 400 IU | 28 | | 65.6 | +0.1 | nd | | | | C
Thomsen 1987^122^ Denmark [3307307] | Early post-menopause, Women | Weight | 2° | 1 y | Ca lactate-gluconate & carbonate 2000 mg | 14 | Kg | 60.6 | +0.4 | −2.4, 3.2^B^ | −0.2 | −8.0, 7.6^B^ | NS | C
Thomsen 1987^122^ Denmark [3307307] | Early post-menopause, Women | Weight | 2° | 1 y | Placebo | 14 | | 66.4 | +0.6 | −6.7, 7.9^B^ | | | | C
Bortolotti 2008^124^ Switzerland [18842771] | Mean (SE) 22 (1.2) y, Both | Weight | 2° | 5 wk | Ca phosphate 800 mg | 10^E^ | Kg | 78.1 | Final 80.0 | | Diff Final +0.4 | −5.7, +6.5 | NS | B
Bortolotti 2008^124^ Switzerland [18842771] | Mean (SE) 22 (1.2) y, Both | Weight | 2° | 5 wk | Placebo | 10^E^ | | 78.1 | 79.6 | | | | | B
Energy Restricted
Kabrnova-Hlavata 2008^123^ Czech Rep [17552880] | 49 (SD) y, Women | Weight | 2° | 3 wk | Ca carbonate 500 mg + 350 mg Ca in diet 4.5 MJ/d) | 21 | Kg | 85.37 | −4.34 | −4.9, −3.8 | −0.47 | −1.4, 0.4^B^ | NS | B
Kabrnova-Hlavata 2008^123^ Czech Rep [17552880] | 49 (SD) y, Women | Weight | 2° | 3 wk | Lactoval (Ca phosphate, citrate, & lactate) 500 mg + 350 mg Ca in diet (4.5 MJ/d) | 25 | | 84.95 | −3.34 | −4.0, −2.6 | +0.53 | −0.5, 1.5^B^ | NS | B
Kabrnova-Hlavata 2008^123^ Czech Rep [17552880] | 49 (SD) y, Women | Weight | 2° | 3 wk | Placebo + 350 mg Ca in diet (4.5 MJ/d) | 21 | | 83.43 | −3.87 | −4.6, −3.2 | | | | B
Cifuentes 2004^119^ New Jersey [15213038] | 52–75 y, Women | Weight | 1° | 6 wk | Ca citrate 1200 mg (>=2.5% wt loss goal) | 16 | Kg | 71.5 | −3.6 | −6.4, −0.8^B^ | −0.3^E^ | −4.8, 4.2 | NS | B
Cifuentes 2004^119^ New Jersey [15213038] | 52–75 y, Women | Weight | 1° | 6 wk | Ca citrate 400 mg (>=2.5% wt loss goal) | 16 | | 74.5 | −3.3 | −6.8, 0.2^B^ | | | | B

A Subgroup data available for black and white men and women (4 groups). No substantive differences among groups. All statistically nonsignificant.

B Estimated from reported data

C Adjusted for multiple factors, including baseline weight.

D No data on calcium type

E Crossover study

F Adjusted for multiple factors, including baseline weight

The three systematic reviews explicitly or implicitly used generally different eligibility criteria, resulting in large overlaps in the trials included among the reports.114–116. Overall, the systematic reviews included 42 trials. All systematic reviews separately analyzed calcium supplementation and dairy product intake. The largest, most recent systematic review114 included trials up to 2007, separated isocaloric from energy-restricted trials, but did not perform meta-analysis. The next largest systematic review115 included trials through 2004. The last systematic review,116 through 2001, also did not perform meta-analyses. All the dairy product trials in this review were also included in the most recent systematic review and are thus not discussed further here. Seven more recent calcium supplementation trials not included in any of the systematic reviews were found.117–123

Isocaloric trials

The systematic review by Lanou et al. (2008)114 evaluated 19 isocaloric trials of increased calcium intake in adults. Nine trials compared calcium supplements to placebo; 10 trials compared high calcium dairy intake to lower calcium nondairy intake. The systematic review did not provide details of every included trial, nor was meta-analysis performed. In summary, 16 trials (8 calcium supplement, 8 dairy product) of the 19 trials reported no significant effect of increased calcium intake on body weight, 1 calcium trial found significantly greater weight loss in those receiving calcium supplements, and 2 dairy trials found significantly greater weight gain in those in the dairy product group. This latter finding was theorized to be due to the extra calories from the dairy products.

Seven additional isocaloric trials were not included in the systematic reviews.117–122,124 Four of these trials were conducted in postmenopausal women, two in young women (age early 20s), and one in men and women aged 30 to 34 years. The trials used a variety of calcium compounds with doses ranging from 800 to 2000 mg; one compared dairy (~1250 mg calcium) to nondairy (~375 mg calcium) intakes.120 The studies ranged in duration from 1 month to almost 3 years. Among the studies, one was of methodological quality A, three B, and three C. Methodological limitations included inadequate reporting of methodology or outcomes, statistical issues, high dropout rates, and large difference in baseline weights between groups. The participants’ weights were generally stable, on average changing less than 1 kg during 6 weeks to 3 years of followup. The net weight changes (calcium group minus control group) ranged from −0.8 to +0.5 kg. No trial found a significant effect of calcium.

Findings per calcium intake level

Overall, there was no evidence of different effects related to calcium intake level. No study directly compared a range of calcium intake levels.

Findings per age and sex

The systematic review did not address the question of different effects based on age or sex. Among the additional trials reviewed here, no significant difference was found across trials of different populations. Most were conducted in postmenopausal women.

Energy-restricted diets

The systematic review by Lanou et al. (2008)114 evaluated 11 trials that compared dairy intake (6 trials) or calcium supplements (5 trials) in the setting of energy-restricted diets with the goal of weight loss. Of the six dairy product trials, three were conducted by the same investigators. These three trials all reported significantly more weight loss in participants with high dairy product intake than those with low or no dairy product intake (1137 vs. 430 mg Ca; 1100 vs. 500 mg; 3 vs. <1 servings). The systematic review authors note that due to incomplete reporting in the trials, it was impossible to determine whether the difference in weight loss may have been due to differences in calcium (or dairy) intake or differential compliance with the calorie restriction protocol. One of the five calcium supplement trials, which was part of one of the positive dairy trials by the same researchers, found greater weight loss with calcium supplementation; the others found no significant effect.

The two additional trials not included in the systematic reviews reported no significant effects of calcium supplementation on body weight loss.119,123 Both trials were conducted in overweight women, one trial with a mean age of 49 years and one trial of postmenopausal women. One trial compared two different formulations of 500 mg calcium with placebo in the setting of a low calcium intake (350 mg/day); the other compared higher (1200 mg) to lower (400 mg) doses of calcium citrate. Over 3 or 6 weeks, women in all trial groups lost between 3.3 and 4.3 kg, with no significant differences between those with higher than lower calcium intake.

Findings per calcium intake level

Overall, there was no evidence of different effects related to calcium intake level. No study directly compared a range of calcium intake levels.

Findings per age and sex

The systematic review did not address the question of different effects based on age or sex. The two additional trials did not add any information regarding age or sex subgroups.

Combined isocaloric and energy-restricted diets

Two of the systematic reviews did not separately analyze studies based on background diet (regarding weight). The systematic review by Trowman et al. (2006)115 performed meta-analyses of 13 trials, separately for calcium supplement and dairy product trials. This systematic review found a significant effect of calcium supplements (weighted mean difference = −1.79 [95 percent CI −3.04, −0.55]) suggesting greater weight loss (or smaller weight gain) in adults taking calcium supplements. However, the investigators noted that the difference in effect of calcium supplement trials may be due to significant differences (in aggregate) in the baseline weights of the two arms. Across studies, the calcium supplement group participants had significantly lower body weights at baseline. The meta-analysis of dairy trials found no significant effect of dairy products on body weight. The systematic review by Barr et al. (2003)116 reviewed both calcium supplement and dairy trials; however, the dairy trials were all included in the later systematic review by Lanou et al. (2008)114 and are thus not repeated here. Among the eight trials of calcium supplementation, all but one found no significant effect on body weight. Between the two systematic reviews, over two-thirds of the trials were conducted in post- or perimenopausal women; the mean age of participants (among trials with data reported in the systematic reviews) ranged from 36 to 72 years. Only four of the trials were conducted in men. The range of calcium supplement doses was 700 to 1600 mg/day, with most studies using 1000 mg. The range of calcium intake among the dairy trials was 610 to 2400 mg/day. In the Trowman et al. (2006) systematic review,115 the range of followup durations of the trials was 12 weeks to 3 years. The Barr et al. (2003) systematic review116 included longer duration trials, ranging from 6 months to 4 years.

Findings per calcium intake level

The systematic reviews did not find evidence of differential effects based on calcium intake level (supplement dose or dairy calcium).

Findings per age and sex

The large majority of trials reviewed in the systematic reviews were conducted in postmenopausal women. The systematic reviews did not find evidence of differential effects based on age or sex.

Findings by life stage

- 0–6 mo Not reviewed
- 7 mo – 2 y Not reviewed
- 3 – 8 y Not reviewed
- 9 – 18 y Not reviewed
- 19 – 50 y Many of the trials are applicable to people within this life stage; though relatively few trials included men. For both people on energy-restrictive diets and on isocaloric diets, overall, the evidence suggests no significant effect on body weight with increased calcium intake, either as supplements or from dairy product intake.
- 51 – 70 y The majority of studies are applicable to women within this life stage; few trials included men. The conclusions are the same as for those in the 19–50 y life stage.
- ≥ 71 y The evidence is scant for this life stage. Few of the studies appear to have included people over age 70 years.
- Postmenopause The majority of studies are applicable to postmenopausal women. The conclusions are the same as for those in the 19–50 y life stage.
- Pregnant & lactating women Not reviewed

### Calcium and Cancer

#### Cancer from all cause and total cancer mortality

Synopsis

No qualified systematic review evaluated associations between calcium intake and incidence of all cancer and total cancer mortality. One RCT showed a borderline nonsignificant reduction of the risk of total cancer among healthy postmenopausal women (>55 years old) living in Nebraska (latitude 41°N) who received calcium supplementation (either calcium citrate 1400 mg/d or calcium carbonate 1500 mg/d). However, one cohort study analyzed US AARP cohort (men and women 50–71 y) showed that that total calcium intake was not associated with the risk of total cancer incident.

There is insufficient data to draw a conclusion regarding association between dietary calcium intakes and total cancer mortality.

Detailed presentation

(Tables 54, 55, 56 & 57)

Table 54 Calcium and total cancer mortality: Characteristics of RCTs

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Lappe 2007^52^ Nebraska, US 41° [17556697] | - Health status; - Mean age (range/SD), y; - Male (%) | Mentally and physically fit 67 (7.3) 0 | 25(OH)D: 71.8 nmol/L | Vit D_3_ 1000 IU/d + Ca (citrate 1400 mg/d or carbonate 1500 mg/d) vs. Ca (citrate 1400 mg/d or carbonate 1500 mg/d) vs. placebo

Table 55 Calcium and total cancer incidence or mortality: Characteristics of cohort studies

Author Year Study Name Location (Latitude) [PMID] | Population | | Dietary Calcium intake | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Study Name Location (Latitude) [PMID] | Population | | Dietary Calcium intake | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV exposure | Lifestyle | Comments
Cohort
Park 2009^125^ NIH-AARP US 38°N [19237724] | - Health status; - Mean age (range/), y; - Male (%) | No cancer 50–71 60 | Dietary assessment methodInternal validation? (y/n) | FFQ (NCI-DHQ) USDA NutrientDatabase y | Total cancer risk stratified by quintile of total calcium intake | X | X | X | X | | X | Total calcium intake from diet and supplement
Slob 1993^126^ Amsterdam 52° N [8478144] | - Health status; - Mean age (range),; - y; - Male (%) | nd 53 (40–65) 51 | Dietary assessment methodInternal validation? (y/n) | FFQ no | Cancer mortality stratified by dietary calcium intake quintiles (from foods only) | X | X

Table 56 Calcium and total cancer mortality: Results of RCTs

Author Year Study Name [PMID] | Life Stage | Outcome | 1°/2° | Followup, y | Interventions, Daily Dose | n Event | N Total | Outcome Metric (Comparison) | Result | 95% CI | P Btw | Study Quality
Lappe 2007^52^ nd [17556697] | Post-menopausal women | Incident cancer (all causes) | 2° | 4 | Ca (citrate 1400 mg or carbonate 1500 mg) | 17 | 445 | RR Ca/placebo | 0.53 | 0.27, 1.03 | 0.06 | B
Lappe 2007^52^ nd [17556697] | Post-menopausal women | Incident cancer (all causes) | 2° | 4 | Placebo | 20 | 288 | | | | | B
Lappe 2007^52^ nd [17556697] | Post-menopausal women | Incident cancer (restrict to subjects who were free of cancer at 1 y intervention) | 2° | 4 | Ca (citrate 1400 mg or carbonate 1500 mg) | 15 | 416 | RR Ca/placebo | 0.59 | 0.29, 1.21 | 0.147
Lappe 2007^52^ nd [17556697] | Post-menopausal women | Incident cancer (restrict to subjects who were free of cancer at 1 y intervention) | 2° | 4 | Placebo | 18 | 266

Table 57 Calcium and total cancer incidence or mortality: Results of cohort studies

Author Year Study Name [PMID] | Life Stage | Outcome (n/N; Incidence) | Followup Duration (Time to Dx) | Total Ca Intake, mg/day | No. of Cases | No. in Category | Adjusted OR | 95% CI | P for Trend | Study Quality
Park 2009 NIH-AARP125 [19237724] | 50–71, males | Total cancer (36,965/3,383,377 person-years) | 7 y | 526 | 36,965 (total) | 3,383,377 person-years (total, both males and females) | 1 (HR) | Reference | 0.74 | B
Park 2009 NIH-AARP125 [19237724] | 50–71, males | Total cancer (36,965/3,383,377 person-years) | 7 y | 498 | | | 0.99 | 0.96, 1.03 | 0.74 | B
Park 2009 NIH-AARP125 [19237724] | 50–71, males | Total cancer (36,965/3,383,377 person-years) | 7 y | 857 | | | 0.99 | 0.96, 1.03 | 0.74 | B
Park 2009 NIH-AARP125 [19237724] | 50–71, males | Total cancer (36,965/3,383,377 person-years) | 7 y | 1073 | | | 0.95^A^ | 0.96, 1.03 | 0.74 | B
Park 2009 NIH-AARP125 [19237724] | 50–71, males | Total cancer (36,965/3,383,377 person-years) | 7 y | 1530 | | | 0.99 | 0.95, 1.03 | 0.74 | B
Park 2009 NIH-AARP125 [19237724] | 50–71, females | Total cancer (16,605/3,383,377 person-years) | 7 y | 494 | 16,605 (total) | 3,383,377 person-years (total, both males and females) | 1 (HR) | Reference | 0.23
Park 2009 NIH-AARP125 [19237724] | 50–71, females | Total cancer (16,605/3,383,377 person-years) | 7 y | 717 | | | 0.98 | 0.93, 1.03 | 0.23
Park 2009 NIH-AARP125 [19237724] | 50–71, females | Total cancer (16,605/3,383,377 person-years) | 7 y | 969 | | | 0.94 | 0.89, 0.99* | 0.23
Park 2009 NIH-AARP125 [19237724] | 50–71, females | Total cancer (16,605/3,383,377 person-years) | 7 y | 1296 | | | 0.93 | 0.88, 0.98* | 0.23
Park 2009 NIH-AARP125 [19237724] | 50–71, females | Total cancer (16,605/3,383,377 person-years) | 7 y | 1881 | | | 0.96 | 0.91, 1.02 | 0.23
Slob 1993^126^ nd [8478144] | 40–65 y, males | Cancer mortality (232/1553; 0.15) | 28 y | ≤585 | nd | nd | 1.0 | 0.6, 1.6 | nd | C
Slob 1993^126^ nd [8478144] | 40–65 y, males | Cancer mortality (232/1553; 0.15) | 28 y | 585 to ≤725 | nd | nd | 1.0 | 0.6, 1.6 | nd | C
Slob 1993^126^ nd [8478144] | 40–65 y, males | Cancer mortality (232/1553; 0.15) | 28 y | 725 to ≤935 | nd | nd | 1.0 | 0.6, 1.5 | nd | C
Slob 1993^126^ nd [8478144] | 40–65 y, males | Cancer mortality (232/1553; 0.15) | 28 y | 935 to ≤1245 | nd | nd | 0.8 | 0.5, 1.3 | nd | C
Slob 1993^126^ nd [8478144] | 40–65 y, males | Cancer mortality (232/1553; 0.15) | 28 y | >1245 | nd | nd | 1.0 | Reference | nd | C
Slob 1993^126^ nd [8478144] | 40–65 y, females | Cancer mortality (127/1397; 0.09) | 28 y | ≤445 | nd | nd | 1.1 | 0.6, 2.1 | nd
Slob 1993^126^ nd [8478144] | 40–65 y, females | Cancer mortality (127/1397; 0.09) | 28 y | 445 to ≤540 | nd | nd | 0.8 | 0.4, 1.5 | nd
Slob 1993^126^ nd [8478144] | 40–65 y, females | Cancer mortality (127/1397; 0.09) | 28 y | 540 to ≤640 | nd | nd | 1.6 | 0.9, 2.8 | nd
Slob 1993^126^ nd [8478144] | 40–65 y, females | Cancer mortality (127/1397; 0.09) | 28 y | 640 to ≤850 | nd | nd | 1.4 | 0.7, 2.5 | nd
Slob 1993^126^ nd [8478144] | 40–65 y, females | Cancer mortality (127/1397; 0.09) | 28 y | >850 | nd | nd | 1.0 | Reference | nd

A Not a reasonable number based on the reported confidence interval; probably a typographical error in the article.

A 4-year population-based RCT,52 sampled from a 9-county, largely rural area in eastern Nebraska (latitude 41°N), aimed to compare the efficacy of vitamin D_3_ (1000 IU/d) plus calcium (either calcium citrate 1400 mg/d or calcium carbonate 1500 mg/d) or calcium alone (either calcium citrate 1400 mg/d or calcium carbonate 1500 mg/d) to placebo in reducing fracture incidence. Incidence of cancer was a secondary outcome of this trial. A total of 743 postmenopausal women over 55 years old were analyzed for the effect of calcium supplementation alone. The mean serum 25(OH)D concentration at baseline was 72 nmol/L.

At the end of study the relative risk of developing cancer was 0.53 (95 percent CI 0.27, 1.03; P=0.06) comparing calcium supplementation (either calcium citrate 1400 mg/d or calcium carbonate 1500 mg/d) to the placebo. This study was rated B.

A cohort study analyzed data from AARP (the American Association of Retired Persons) members, aged 50 to 71 years old, living in six specific states in the US.125 During 3,383,377 person-years of followup (over 7 years), a total of 36,965 cancer cases in men and 16,605 cancer cases in women were identified. The results showed that that total calcium intake was not associated with the risk of total cancer after controlling for potential risk factors pertinent to individual cancers. Methodological quality of this study was rated B.

Findings by age, sex and/or ethnicity

A cohort study analyzing a total of 1553 men and 1397 women, aged between 40 and 65 years, living in Amsterdam (52°N) showed that there was no significant association between dietary calcium from foods and total cancer mortality in either men or in women after 28 years of followup.126 This study was rated C because the food frequency questionnaire was not internally validated and could not estimate usual intake through 1-week food frequency recall.

Findings by life stage

- 0 – 6 mo No data
- 7 mo – 2 y No data
- 3 – 8 y No data
- 9 – 18 y No data
- 19 – 50 y A cohort study in Amsterdam included some men and women in this life stage. However, this study provided insufficient data regarding association between dietary calcium intakes and total cancer mortality.
- 51 – 70 y The cohort study in Amsterdam also included some men and women in this life stage. However, this study provided insufficient data regarding association between dietary calcium intakes and total cancer mortality. One study analyzed US AARP cohort with men and women in this life stage showed that that total calcium intake was not associated with the risk of total cancer incident
- ≥71 y No data
- Postmenopause One RCT with healthy postmenopausal women showed a borderline nonsignificant reduction of risk of total cancer by calcium supplementation (either calcium citrate 1400 mg/d or calcium carbonate 1500 mg/d).
- Pregnant & lactating women No data

#### Prostate cancer

We reviewed primary studies that evaluated associations between calcium intake and incidence and mortality of prostate cancer.

Synopsis

No trials of calcium interventions evaluated prostate cancer. Four cohort studies rated A in methodological quality reported on the association between total calcium intake and the risk of prostate cancer. Three studies found significant associations between higher calcium intake and increased risk of prostate cancer. One study found the risk was higher in the group that took more than 1500 mg/d of calcium compared to those that took less than 700 mg/d (adjusted RR 1.3). A second study found only the group that took more than 2000 mg/d of calcium had higher risk of prostate cancer compared to those that took 500 to 749 mg/d of calcium (adjusted RR 1.26). A third study also found that male smokers who took more than 2000 mg/d of calcium had higher risk compared to those who took less than 1000 mg/d (adjusted RR 1.63). The fourth study found no relation between calcium intake (<500 to ≥2000 mg/d) and the risk of prostate cancer in men aged 50–70 years.

Detailed presentation

(Tables 58 & 59; Figure 13)

Table 58 Calcium and prostate cancer: Characteristics of observational studies

Author, Year Trial/Cohort Name Country (Latitude) [PMID] | Population | | Dietary calcium intake | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author, Year Trial/Cohort Name Country (Latitude) [PMID] | Population | | Dietary calcium intake | | Comparisons | Nutrients | Demographic | Anthrop | Medical | UV exposure | Life styles | Comments
Park 2007^134^ NIH-AARP Diet & Health US (multiple latitudes) [18000020] | Health status Mean age (range/SD), y Male (%) | 12% current smoker 50–71 (est.) 100 | Dietary assessment method Internal validation? (y/n) | 124-item FFQ y | Prostate cancer risk stratified by different intakes of calcium (dietary and supplement combined) | X | X | X | X | | X | 92% white; Total Ca (both)
Rodriguez 2003^135^ CPS II Nutrition Cohort US (multiple latitudes) [12869397] | Health status Mean age (range/SD), y Male (%) | 9.5% current smoker 64 100 | Dietary assessment method Internal validation? (y/n) | 68-item FFQ (modified Block) y | Prostate cancer risk stratified by different intakes of calcium (dietary and supplement combined & dietary calcium alone) | X | X | X | | | X | Total Ca (both)
Giovannucci 2006^128^ 2007^129^ HPFS US (multiple latitudes) [16492906] [17450530] | Health status Mean age (range/SD), y Male (%) | ~10% current smoker 40–75 100 | Dietary assessment method Internal validation? (y/n) | Semi-quantitative FFQ y | Prostate cancer risk stratified by different intakes of calcium (dietary and supplement combined) | X | X | X | X | | X | >91% white; Total Ca (both)
Mitrou 2007^132^ ATBC Finland (60°N) [17106437] | Health status Mean age (range/SD), y Male (%) | all smokers 57 (est.) 100 | Dietary assessment method Internal validation? (y/n) | 276-item FFQ y | Prostate cancer risk stratified by different intakes of calcium (dietary and supplement combined) | X | X | X | X | | X | 100% white; Total Ca (food)
Park 2007^133^ MCS, HI, CA US (multiple latitudes) [17925283] | Health status Mean age (range/SD), y Male (%) | ~17% current smoker 45–75 100 | Dietary assessment method Internal validation? (y/n) | self-administered FFQ y | Prostate cancer risk stratified by different intakes of dietary calcium | X | X | X | | | X | ~equal % of African Americans, native Hawaiians, Japanese Americans, Hispanics, whites; Total Ca (both)
Chan 2001^127^ PHS US (multiple latitudes) [11566656] | Health status Mean age (range/SD), y Male (%) | on ASA, β-carotene, placebo trial; ~11% current smoker 53 100 | Dietary assessment method Internal validation? (y/n) | short self-administered questionnaire n | Prostate cancer risk stratified by different intakes of dietary calcium | | X | X | | | X | Total Ca (dairy)
Koh 2006^130^ HAH US (multiple latitudes) [17106437] | Health status Mean age (range/SD), y Male (%) | 7.5% smoker 67 100 | Dietary assessment method Internal validation? (y/n) | 23-item FFQ (Willett 1985, 1987) n | Prostate cancer risk stratified by different intakes of dietary calcium | X | X | X | | | X | Total Ca (dairy)
Schurrman 1999^137^ Netherlands Cohort (52°N) [10362125] | Health status Mean age (range/SD), y Male (%) | nd 61 100 | Dietary assessment method Internal validation? (y/n) | 150-item semi-quantitative FFQ n | Prostate cancer risk stratified by quintile of dietary calcium intakes | X | X | | | | | Total Ca (food)
Kurahashi 2008^131^ Japan PHC (multiple latitudes) [18398033] | Health status Mean age (range/SD), y Male (%) | ~44% current smoke 45–74 100 | Dietary assessment method Internal validation? (y/n) | FFQ y | Prostate cancer risk stratified by quartiles of dietary calcium intakes | X | X | | | | X | Total Ca (food)
Rohrmann 2007^136^ WCC, MD US (39°N) [17315319] | Health status Mean age (range/SD), y Male (%) | 17% current smoker 54 100 | Dietary assessment method Internal validation? (y/n) | 60-item FFQ (Block) n | Prostate cancer risk stratified by tertiles of calcium intakes (dietary and supplement combined) | X | X | X | | | | 99% white; Total Ca (both)
Tseng 2005^138^ NHEFS US (multiple latitudes) [15883441] | Health status Mean age (range/SD), y Male (%) | nd 58 (14.6) 100 | Dietary assessment method Internal validation? (y/n) | 105-item FFQ n | Prostate cancer risk stratified by tertiles of calcium intakes (dietary and supplement combined) | X | X | | | X | X | 88% white; 11% black; Total Ca (both)
Baron 2005^56^ CPP US (multiple latitudes) [15767334] | Health status Mean age (range/SD), y Male (%) | had >1 colon adenoma removal 62 (8.7) 100 | Dietary assessment method Internal validation? (y/n) | FFQ (Block, 1986) N | Prostate cancer risk stratified by tertiles of dietary calcium intakes | X | X | | | | | 5% black; Total Ca (suppl)

Table 59 Calcium and prostate cancer: Results of observational studies

Author Year Study Name [PMID] | Life Stage (male), y | Outcome (n/N; Incidence) | Followup Duration | Total Ca intake in mg/d | No. of Cases | Total no. in Category | Adjusted RR | 95% CI | P for Trend | Study Quality
Park 2007^134^ NIH-AARP Diet & Health [18000020] | 51–70 | Prostate cancer (10,180/293,888; 0.035) | 8 y | <500 | 767 | nd | 1.01 | 0.93, 1.10 | 0.41 | A
Park 2007^134^ NIH-AARP Diet & Health [18000020] | 51–70 | Prostate cancer (10,180/293,888; 0.035) | 8 y | 500-<750 | 2927 | nd | 1 | Reference | 0.41 | A
Park 2007^134^ NIH-AARP Diet & Health [18000020] | 51–70 | Prostate cancer (10,180/293,888; 0.035) | 8 y | 750-<1000 | 2808 | nd | 0.99 | 0.93, 1.04 | 0.41 | A
Park 2007^134^ NIH-AARP Diet & Health [18000020] | 51–70 | Prostate cancer (10,180/293,888; 0.035) | 8 y | 1000-<1500 | 2572 | nd | 0.99 | 0.93, 1.05 | 0.41 | A
Park 2007^134^ NIH-AARP Diet & Health [18000020] | 51–70 | Prostate cancer (10,180/293,888; 0.035) | 8 y | 1000-<1500 | 2572 | nd | 0.99 | 0.93, 1.05 | 0.41 | A
Park 2007^134^ NIH-AARP Diet & Health [18000020] | 51–70 | Prostate cancer (10,180/293,888; 0.035) | 8 y | ≥2000 | 309 | nd | 0.97 | 0.85, 1.10 | 0.41 | A
Park 2007^134^ NIH-AARP Diet & Health [18000020] | 51–70 | Mortality Prostate cancer | | <500 | 11 | nd | 0.76 | 0.38, 1.53 | 0.99 | A
Park 2007^134^ NIH-AARP Diet & Health [18000020] | 51–70 | Mortality Prostate cancer | | 500-<750 | 43 | nd | 1 | Reference | 0.99 | A
Park 2007^134^ NIH-AARP Diet & Health [18000020] | 51–70 | Mortality Prostate cancer | | 750-<1000 | 56 | nd | 1.50 | 0.97, 2.32 | 0.99 | A
Park 2007^134^ NIH-AARP Diet & Health [18000020] | 51–70 | Mortality Prostate cancer | | 1000-<1500 | 50 | nd | 1.42 | 0.86, 2.35 | 0.99 | A
Park 2007^134^ NIH-AARP Diet & Health [18000020] | 51–70 | Mortality Prostate cancer | | 1500-<2000 | 18 | nd | 1.05 | 0.54, 2.05 | 0.99 | A
Park 2007^134^ NIH-AARP Diet & Health [18000020] | 51–70 | Mortality Prostate cancer | | ≥2000 | 0 | nd | - | - | 0.99 | A
Rodriguez 2003^135^ CPS II [12869397] | 51–70 | Prostate cancer (3811/65,321; 0.058) | ≤7 y | <700 | 1323 | 23,653 | 1 | Reference | 0.02 | A
Rodriguez 2003^135^ CPS II [12869397] | 51–70 | Prostate cancer (3811/65,321; 0.058) | ≤7 y | 700–999 | 1293 | nd | 1.0 | 0.9, 1.1 | 0.02 | A
Rodriguez 2003^135^ CPS II [12869397] | 51–70 | Prostate cancer (3811/65,321; 0.058) | ≤7 y | 1000–1499 | 835 | nd | 1.0 | 0.9, 1.1 | 0.02 | A
Rodriguez 2003^135^ CPS II [12869397] | 51–70 | Prostate cancer (3811/65,321; 0.058) | ≤7 y | 1500–1999 | 265 | nd | 1.3 | 1.1, 1.5^*^ | 0.02 | A
Rodriguez 2003^135^ CPS II [12869397] | 51–70 | Prostate cancer (3811/65,321; 0.058) | ≤7 y | ≥2000 | 95 | 1330 | 1.2 | 1.0, 1.6^*^ | 0.02 | A
Giovannucci 2006^128^ 2007^129^ HPFS [16492906] [17450530] | 19–50 51–70 | Prostate cancer (3544/47,750; 0.074) | ≤16 y | <500 | 183 | nd | 0.98 | 0.84, 1.15 | 0.10 | A
Giovannucci 2006^128^ 2007^129^ HPFS [16492906] [17450530] | 19–50 51–70 | Prostate cancer (3544/47,750; 0.074) | ≤16 y | 750–999 | 1099 | nd | 1.07 | 0.98, 1.16 | 0.10 | A
Giovannucci 2006^128^ 2007^129^ HPFS [16492906] [17450530] | 19–50 51–70 | Prostate cancer (3544/47,750; 0.074) | ≤16 y | 500–749 | 1072 | nd | 1 | Reference | 0.10 | A
Giovannucci 2006^128^ 2007^129^ HPFS [16492906] [17450530] | 19–50 51–70 | Prostate cancer (3544/47,750; 0.074) | ≤16 y | 1500–1999 | 207 | nd | 1.06 | 0.91, 1.23 | 0.10 | A
Giovannucci 2006^128^ 2007^129^ HPFS [16492906] [17450530] | 19–50 51–70 | Prostate cancer (3544/47,750; 0.074) | ≤16 y | 1000–1499 | 898 | nd | 1.03 | 0.94, 1.14 | 0.10 | A
Giovannucci 2006^128^ 2007^129^ HPFS [16492906] [17450530] | 19–50 51–70 | Prostate cancer (3544/47,750; 0.074) | ≤16 y | ≥2000 | 85 | nd | 1.28 | 1.02, 1.60^*^ | 0.10 | A
Giovannucci 2006^128^ 2007^129^ HPFS [16492906] [17450530] | 19–50 51–70 | Mortality Prostate cancer | | <500 | 21 | nd | 1.05 | 0.65, 1.69 | 0.01 | A
Giovannucci 2006^128^ 2007^129^ HPFS [16492906] [17450530] | 19–50 51–70 | Mortality Prostate cancer | | 750–999 | 81 | nd | 0.95 | 0.70, 1.28 | 0.01 | A
Giovannucci 2006^128^ 2007^129^ HPFS [16492906] [17450530] | 19–50 51–70 | Mortality Prostate cancer | | 500–749 | 94 | nd | 1 | Reference | 0.01 | A
Giovannucci 2006^128^ 2007^129^ HPFS [16492906] [17450530] | 19–50 51–70 | Mortality Prostate cancer | | 1500–1999 | 26 | nd | 1.56 | 1.0, 2.43^*^ | 0.01 | A
Giovannucci 2006^128^ 2007^129^ HPFS [16492906] [17450530] | 19–50 51–70 | Mortality Prostate cancer | | 1000–1499 | 76 | nd | 1.04 | 0.77, 1.42 | 0.01 | A
Giovannucci 2006^128^ 2007^129^ HPFS [16492906] [17450530] | 19–50 51–70 | Mortality Prostate cancer | | ≥2000 | 14 | nd | 2.02 | 1.14, 3.58^*^ | 0.01 | A
Mitrou 2007^132^ ATBC [17106437] | 51–70 | Prostate cancer (1267/27,028; 0.047) | ≤17 y | <1000^A^ | 151 | nd | 1 | Reference | <0.0001 | A
Mitrou 2007^132^ ATBC [17106437] | 51–70 | Prostate cancer (1267/27,028; 0.047) | ≤17 y | 1000–1499 | 611 | nd | 1.28 | 1.07, 1.54^*^ | <0.0001 | A
Mitrou 2007^132^ ATBC [17106437] | 51–70 | Prostate cancer (1267/27,028; 0.047) | ≤17 y | 1500–1999 | 402 | nd | 1.38 | 1.14, 1.67^*^ | <0.0001 | A
Mitrou 2007^132^ ATBC [17106437] | 51–70 | Prostate cancer (1267/27,028; 0.047) | ≤17 y | ≥2000 | 103 | nd | 1.63 | 1.27, 2.10^*^ | <0.0001 | A
Park 2007^133^ MCS [17925283] | 19–50 51–70 | Prostate cancer (4404/82,483; 0.053) | 8 y | <470 | 706 | nd | 1 | Reference | 0.69 | B
Park 2007^133^ MCS [17925283] | 19–50 51–70 | Prostate cancer (4404/82,483; 0.053) | 8 y | 470–692 | 925 | nd | 1.03 | 0.93, 1.15 | 0.69 | B
Park 2007^133^ MCS [17925283] | 19–50 51–70 | Prostate cancer (4404/82,483; 0.053) | 8 y | 692–935 | 949 | nd | 1.04 | 0.93, 1.17 | 0.69 | B
Park 2007^133^ MCS [17925283] | 19–50 51–70 | Prostate cancer (4404/82,483; 0.053) | 8 y | 935–1300 | 936 | nd | 1.05 | 0.93, 1.18 | 0.69 | B
Park 2007^133^ MCS [17925283] | 19–50 51–70 | Prostate cancer (4404/82,483; 0.053) | 8 y | ≥1301 | 888 | nd | 1.04 | 0.91, 1.20 | 0.69 | B
Chan 2001^127^ PHS [11566656] | 51–70 | Prostate cancer (1012/20,885; 0.048) | ≤11 y | 0–150^A^ | 155 | nd | 1 | Reference | 0.05 | B
Chan 2001^127^ PHS [11566656] | 51–70 | Prostate cancer (1012/20,885; 0.048) | ≤11 y | 151–300 | 206 | nd | 1.21 | 0.96, 1.53 | 0.05 | B
Chan 2001^127^ PHS [11566656] | 51–70 | Prostate cancer (1012/20,885; 0.048) | ≤11 y | 301–600 | 377 | nd | 1.35 | 1.09, 1.66^*^ | 0.05 | B
Chan 2001^127^ PHS [11566656] | 51–70 | Prostate cancer (1012/20,885; 0.048) | ≤11 y | >600 | 274 | nd | 1.29 | 1.04, 1.62^*^ | 0.05 | B
Koh 2006^130^ HAH [17106437] | 51–70 | Prostate cancer (815/10,011; 0.081) | ≤10 y | 0–199^A^ | 209 | nd | 1 | Reference | 0.64 | B
Koh 2006^130^ HAH [17106437] | 51–70 | Prostate cancer (815/10,011; 0.081) | ≤10 y | 200–449 | 167 | nd | 0.81 | 0.64, 1.02 | 0.64 | B
Koh 2006^130^ HAH [17106437] | 51–70 | Prostate cancer (815/10,011; 0.081) | ≤10 y | 450–599 | 238 | nd | 0.91 | 0.73, 1.14 | 0.64 | B
Koh 2006^130^ HAH [17106437] | 51–70 | Prostate cancer (815/10,011; 0.081) | ≤10 y | ≥600 | 201 | nd | 0.91 | 0.70, 1.18 | 0.64 | B
Koh 2006^130^ HAH [17106437] | 51–70 | Mortality Prostate cancer | | 0–199 | 30 | nd | 1.00 | Reference | 0.52 | B
Koh 2006^130^ HAH [17106437] | 51–70 | Mortality Prostate cancer | | 200–449 | 21 | nd | 0.57 | 0.27, 1.19 | 0.52 | B
Koh 2006^130^ HAH [17106437] | 51–70 | Mortality Prostate cancer | | 450–599 | 23 | nd | 0.60 | 0.29, 1.22 | 0.52 | B
Koh 2006^130^ HAH [17106437] | 51–70 | Mortality Prostate cancer | | ≥600 | 25 | nd | 0.81 | 0.38, 1.71 | 0.52 | B
Schuurman 1999^137^ Netherlands Cohort [10362125] | 51–70 | Prostate cancer (704/58,279; 0.012) | ≤6.3 y | 602^A,B^ | 120 | nd | 1 | Reference | 0.34 | B
Schuurman 1999^137^ Netherlands Cohort [10362125] | 51–70 | Prostate cancer (704/58,279; 0.012) | ≤6.3 y | 780 | 126 | nd | 1.10 | 0.80, 1.51 | 0.34 | B
Schuurman 1999^137^ Netherlands Cohort [10362125] | 51–70 | Prostate cancer (704/58,279; 0.012) | ≤6.3 y | 911 | 127 | nd | 1.04 | 0.76, 1.42 | 0.34 | B
Schuurman 1999^137^ Netherlands Cohort [10362125] | 51–70 | Prostate cancer (704/58,279; 0.012) | ≤6.3 y | 1064 | 140 | nd | 1.21 | 0.89, 1.66 | 0.34 | B
Schuurman 1999^137^ Netherlands Cohort [10362125] | 51–70 | Prostate cancer (704/58,279; 0.012) | ≤6.3 y | 1329 | 129 | nd | 1.09 | 0.79, 1.50 | 0.34 | B
Kurahashi 2008^131^ Japan PHC [18398033] | 19–50 51–70 | Prostate cancer (329/43,435; 0.008) | ≤7.5 y | 283^A,B^ | 56 | nd | 1 | Reference | 0.16 | B
Kurahashi 2008^131^ Japan PHC [18398033] | 19–50 51–70 | Prostate cancer (329/43,435; 0.008) | ≤7.5 y | 404 | 68 | nd | 1.03 | 0.70, 1.51 | 0.16 | B
Kurahashi 2008^131^ Japan PHC [18398033] | 19–50 51–70 | Prostate cancer (329/43,435; 0.008) | ≤7.5 y | 522 | 98 | nd | 1.32 | 0.92, 1.90 | 0.16 | B
Kurahashi 2008^131^ Japan PHC [18398033] | 19–50 51–70 | Prostate cancer (329/43,435; 0.008) | ≤7.5 y | 725 | 107 | nd | 1.24 | 0.85, 1.81 | 0.16 | B
Rohrmann 2007^136^ WCC [17315319] | 51–70 | Prostate cancer (199/3892; 0.051) | ≤15 y | <686 | 58 | nd | 1 | Reference | 0.99 | B
Rohrmann 2007^136^ WCC [17315319] | 51–70 | Prostate cancer (199/3892; 0.051) | ≤15 y | 686–958 | 65 | nd | 0.98 | 0.72, 1.47 | 0.99 | B
Rohrmann 2007^136^ WCC [17315319] | 51–70 | Prostate cancer (199/3892; 0.051) | ≤15 y | >958 | 76 | nd | 0.99^C^ | 0.70, 1.41 | 0.99 | B
Tseng 2005^138^ NHEFS [15883441] | 51–70 | Prostate cancer (131/3779; 0.035) | 7.7 y | 455^B^ | 28 | nd | 1 | Reference | 0.001 | B
Tseng 2005^138^ NHEFS [15883441] | 51–70 | Prostate cancer (131/3779; 0.035) | 7.7 y | 642 | 37 | nd | 1.0 | 0.6, 1.7 | 0.001 | B
Tseng 2005^138^ NHEFS [15883441] | 51–70 | Prostate cancer (131/3779; 0.035) | 7.7 y | 921 | 66 | nd | 2.2 | 1.4, 3.5^*^ | 0.001 | B
Baron2005^56^ CPP [15767334] | 51–70 | Prostate cancer (70/672; 0.10) | ≤12 y | <675^A,B^ | nd | nd | 1 | Reference | 0.51 | C
Baron2005^56^ CPP [15767334] | 51–70 | Prostate cancer (70/672; 0.10) | ≤12 y | 675–991 | nd | nd | 1.48 | 0.81, 2.70 | 0.51 | C
Baron2005^56^ CPP [15767334] | 51–70 | Prostate cancer (70/672; 0.10) | ≤12 y | >991 | nd | nd | 1.20 | 0.64, 2.23 | 0.51 | C

* Statistically significant (P<0.05)

A Dietary calcium

B median of tertile, quartile or quintile

C Adjusted hazard ratio

Figure 13 Prostate cancer risk stratified by calcium intake

A total of 12 cohort studies in 13 publications reported on the association between calcium intake and the risk of prostate cancer.56,127–138 One of the studies also provided a post hoc analysis of an RCT on calcium supplement.56 The incidence of prostate cancer in these studies ranged from 0.008 to 0.10. Most of the studies were conducted in Europe or North America, one study was conducted in Japan. Mean age of the subjects ranged from 53 to 67 years. Total calcium intake ranged from less than 500 mg/d to at least 2000 mg/d. Time between dietary assessment and the diagnosis of prostate cancer varied from 1 to 17 years. Methodological quality of four studies was rated A, seven studies were rated B, and one study was rated C.

19–50 years

No study specifically targeted men between 19 to 50 years old.

51–70 years

Twelve studies reported data on subjects with a mean age ranged from 53 to 67 years. Seven studies did not find an association between calcium intake and the risk of prostate cancer.56,130,131,133,134,136,137 Five studies found that the risk was higher in the groups that took more calcium compared to the groups that took lower amount (adjusted OR 1.2–2.2).127,129,132,135,138 The higher amount ranged from 921 to at least 2000 mg/d of calcium; the lower amount ranged from 455 to 1000 mg/d. Three studies also reported on the association between calcium intake and mortality from prostate cancer. Two studies found no association130,134 and one study found an increased risk comparing the group that took at least 2000 mg/d of calcium with the group that took 500 to 749 mg/d (adjusted RR 2.02, 95 percent CI 1.14, 3.58).129 One study was a post hoc analysis of an RCT of high calcium supplement (1200 mg/d) to prevent colorectal adenoma.56 This study did not find an increased risk of prostate cancer in those supplemented with calcium compared to those who were not (unadjusted RR 0.83, 95 percent CI 0.52, 1.32). This study did not adjust for factors potentially relevant to prostate cancer.

Findings by life stage

- 6 mo Not applicable
- 7 mo–2 y Not applicable
- 3–8 y Not applicable
- 9–18 y Not reviewed
- 19–50 y No study specifically targeted men 19 to 50 years old.
- 51–70 y Seven studies did not find an association between calcium intake and the risk of prostate cancer. Five studies found that the risk was higher in the groups that took more calcium compared to the groups that took lower amount (adjusted OR 1.2–2.2). The higher amount ranged from 921 to at least 2000 mg/d; the lower amount ranged from 455 to 1000 mg/d.
- ≥71 y No study specifically targeted men older than 70 years.
- Postmenopause Not applicable
- Pregnant & lactating women Not applicable

#### Colorectal cancer

Synopsis

This synopsis is based on one systematic review, 19 cohort studies in 20 publications, and one nested case-control study. The systematic review of two RCTs that evaluated high risk population found no difference in colorectal cancer incidence between those participants who received supplemental calcium and those who did not. Among five cohort studies and one nested case-control study with methodological quality B, two cohort studies showed a significant inverse association between total calcium intake and colorectal cancer. Among 14 cohort studies with methodological quality C, five studies showed a significant inverse association between total calcium intake and colorectal cancer, one found an inverse association between total calcium intake and colon cancer, and two showed an inverse association between calcium and rectal cancer. All the studies that found a significant association recruited men or women who were followed for a period that ranged between 1.4 and 11.3 years. None of these studies included participants younger than 45 years.

Detailed presentation

(Tables 60, 61, 62 & 63; Figures 14, 15, 16, 17 & 18)

Table 60 Systematic review of calcium supplementation and colorectal cancer incidence or adenoma recurrence

Author Year [PMID] | Weingarten, 2008^139^ [18254022]
Design | Randomized controlled trials: Cochrane Library Issue 2, 2007, the Cochrane Colorectal Cancer Group (CCCG) specialized register, MEDLINE (1966 to July 2007), Cancerlit (1963 to April 2002), Embase (1980 to July 2007)
Population | Healthy adults and studies of adults at higher risk of colon cancer due to family history, previous adenomatous polyps, or inflammatory bowel disease
Intervention (Exposure) and Comparator | Calcium (>1200 mg/d) vs. placebo
Results | Calcium vs. placebo Colorectal cancer incidence: OR 0.34, CI 0.05–2.15, P=0.20 (I2=0%) Colorectal adenoma recurrence: OR 0.74; 95%CI 0.58, 0.95, P=0.02 (I2=0%) At least one adverse event requiring discontinuation: OR 0.93; 95% CI 0.42, 2.05, P=0.80
Comments | Based only on two RCTs (1346 participants). Heterogeneity due to different dose of supplementation (one RCT supplemented with 1200 mg/d and the other RCT with 2000 mg/d). Analysis based on fixed effects model; however, considering there are only two studies, random effects model might have been more appropriate. The result of no significant difference in colorectal cancer incidence is inconclusive since there were only 5 colorectal cancer cases during the study period. Analysis on adverse events is based only on reported data of one out of the two RCTs (Barron 1999).160 Only participants with high risk due to previous adenomas were recruited in these two RCTs; therefore, applicability of the results can only be considered for high risk population. Insufficient evidence to recommend the general use of calcium supplements to prevent colorectal adenoma or colorectal cancer
AMSTAR
A priori design? | X | Study quality assessment performed? | X
Two independent reviewers? | X | Study quality appropriately used in analysis? | X
Comprehensive literature search? | X | Appropriate statistical synthesis? | X
All publication types and languages included? | | Publication bias assessed? | X
Included and excluded studies listed? | X | Conflicts of interest stated? | X
Study characteristics provided? | X

Table 61 Calcium and colorectal cancer: Characteristics of observational studies

Author, Year Trial/Cohort Name Country (Latitude) [Pubmed ID] | Population | | Dietary Calcium intake | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author, Year Trial/Cohort Name Country (Latitude) [Pubmed ID] | Population | | Dietary Calcium intake | | Comparisons | Nutrients | Demographic | Anthrop | Medical | Seasons | Life styles | Comments
Cohort
Park, 2009^125^ NIH-AARP Diet & Health (various) US [19237724] | - Health status; - Mean age range, yr; - Male (%) | Generally healthy men and women 50–71 60 | - Dietary assessment method; - Internal validation? (y/n) | Semi- quantitative FFQ(NCI- DHQ) y | CRC across 5 categories of total calcium intake | X | X | X | X | | X | White Male ~92%; Female~89%; Total Ca (both)
Wu, 2002^140^ HPFS NHS (various) US [11904316] | - Health status; - Mean age (range/SD), yr; - Male (%) | HPFS: generally healthy male health professionals NHS: generally healthy female nurses HPFS: 54.4 NHS: 46.6 HPFS: 100 NHS: 0 | - Dietary assessment method; - Internal validation? (y/n) | HPFS: 131-item semi-quantitative FFQ (by Willet) NHS: 61-item semi-quantitative FFQ (by Willet) y | For HPFS, NHS separately: CRC across 7 categories of cumulative average calcium intake | X | X | X | X | | X | Total Ca (both)
Kesse, 2005^141^ Etude Epidémiologique auprès de femmes de l’Education Nationale France (46°N) [15880532] | - Health status; - Mean age (range/SD), yr; - Male (%) | Generally healthy women 52.7 0 | - Dietary assessment method; - Internal validation? (y/n) | FFQ y | CRC across total calcium intake quartiles | X | X | X | | | X | Total Ca (food)
Lin, 2005^142^ WHS US (various) [15800268] | - Health status; - Mean age (range/SD), yr; - Male (%) | Generally healthy women nd 0 | - Dietary assessment method; - Internal validation? (y/n) | 131-item FFQ y | CRC across total calcium intake quintiles | X | X | X | X | | X | Total Ca (both)
Pietinen, 1999^143^ ATBC Finland (~64°N) [10530608] | - Health status; - Mean age (range/SD), yr; - Male (%) | Generally healthy men; smokers Median, cases: 60.1; non cases: 57.1 100 | - Dietary assessment method; - Internal validation? (y/n) | 276-item FFQ y | CRC across total calcium intake quartiles | X | X | X | | | X | Total Ca (food)
Park, 2007^144^ The Multiethnic Cohort Study US (various) [17215380] | - Health status; - Mean age (range/SD), yr; - Male (%) | Generally healthy men and women nd 45 | - Dietary assessment method; - Internal validation? (y/n) | FFQ | CRC per gender across total calcium intake quintiles | X | X | X | X | | X | Total Ca (both)
McCullough, 2003^145^ CPS II US (various) [12708719] | - Health status; - Mean age (range/SD), yr; - Male (%) | Generally healthy men and women nd 48 | - Dietary assessment method; - Internal validation? (y/n) | 68-item semi-quantitative FFQ (modification of the brief Health Habits and History Questionnaire (HHHQ) by Block) y | CRC across total calcium intake quintiles Subgroup analyses per gender For men, subgroup analyses per site (colon, rectal) | X | X | X | X | | X | Total Ca (both)
Shin, 2006^149^ Shanghai Women’s Health Study China (31°N) [17019716] | - Health status; - Mean age (range/SD), yr; - Male (%) | Generally healthy women Cases: 59 (8.5); non- cases: 52 (9.1) 0 | - Dietary assessment method; - Internal validation? (y/n) | 77-item FFQ used in Shanghai Women’s Health Study y | CRC across total calcium intake quintiles Subgroup analyses per site (colon, rectal) | X | X | | X | | X | Chinese; Total Ca (food)
Terry, 2002^146^ Swedish Mammograp hy Screening Cohort Sweden (59°N) [12467133] | - Health status; - Mean age (range/SD), yr; - Male (%) | Generally healthy women nd 0 | - Dietary assessment method; - Internal validation? (y/n) | Self- administered 67- item FFQ y | CRC across total calcium intake quartiles Subgroup analyses per site (colon, rectal) Subgroup analyses per age (< 55 vs. ≥ 55 years old) and site(colon, rectal) | X | X | X | | | X | Total Ca (food)
Gaard, 1996^153^ nd Norway (60°–69°N) [9061275] | - Health status; - Mean age (range/SD), yr; - Male (%) | Generally healthy men and women 43 49 | - Dietary assessment method; - Internal validation? (y/n) | semi- quantitative FFQ(Oslo University) y | Colon cancer per gender across total calcium intake quartiles | | X | X | | | X | Total Ca (food)
Flood, 2005^147^ The Breast Cancer Detection Demonstration Project (BCDDP) US (various) [15668485]) | - Health status; - Mean age (range/SD), yr; - Male (%) | Generally healthy women 61.9 0 | - Dietary assessment method; - Internal validation? (y/n) | 62-item semi-quantitative FFQ (by Block) | CRC cancer across total calcium intake quintiles Subgroup analyses per site (colon, rectal) | X | X | X | X | | X | Total Ca (both)
Larsson, 2006^148^ The Cohort of Swedish Men Sweden (59°N) [16522915] | - Health status; - Mean age (range/SD), yr; - Male (%) | Generally healthy men 60.3 100 | - Dietary assessment method; - Internal validation? (y/n) | 96-item semi- quantitative FFQ y | CRC across total calcium intake quartiles Subgroup analyses per site (colon, rectal) | X | X | X | X | | X | Total Ca (both)
Bostick, 1993^150^ Iowa Women’s Health Study US (40°N) [8333412] | - Health status; - Mean age (range/SD), yr; - Male (%) | Generally healthy post- menopausal women 61.5 0 | - Dietary assessment method; - Internal validation? (y/n) | 127-item semi- quantitative FFQ (by Willet) y | Colon cancer across total calcium intake quintiles | X | X | X | | | | Same cohort as Zheng1998; Total Ca (both)
Zheng, 1998^152^ Iowa Women’s Health Study US (40°N) [9521437] | - Health status; - Mean age (range/SD), yr; - Male (%) | Generally healthy post- menopausal women 61.5 0 | - Dietary assessment method; - Internal validation? (y/n) | 127-item semi- quantitative FFQ (by Willet) y | Rectal cancer across total calcium intake tertiles | X | X | X | X | | X | Same cohort as Bostick 1993; Total Ca (both)
Kato, 1997^155^ New York University Women’s Health Study US (various) [9343837] | - Health status; - Mean age (range/SD), yr; - Male (%) | Generally healthy women nd 0 | - Dietary assessment method; - Internal validation? (y/n) | 70-item semi- quantitative FFQ (slightly modified from Block’s) y | CRC across total calcium intake quartiles | X | X | | | | | Total Ca (food)
Wu, 1987^154^ US (21°N) [3620314] | - Health status; - Mean age (range/SD), yr; - Male (%) | Generally healthy men and women nd 33 | - Dietary assessment method; - Internal validation? (y/n) | 56-item FFQ n | CRC per gender across total calcium intake tertiles | | X | | | | | Total Ca (dairy)
Jarvinen, 2001^157^ nd Finland (64°N) | - Health status; - Mean age (range/SD), yr; - Male (%) | Generally healthy men and women 39.1 nd | - Dietary assessment method; - Internal validation? (y/n) | Diet history y | CRC across total calcium intake quartiles Subgroup analyses per site (colon, rectal) | X | X | X | | | X | Total Ca (food)
Stemmermann, 1990^151^ Japan Hawaii Cancer Study US (21°N) [2311461] | - Health status; - Mean age (range/SD), yr; - Male (%) | Generally healthy men nd 100 | - Dietary assessment method; - Internal validation? (y/n) | 24-hour diet recall interview y | Colon cancer across total calcium intake tertiles | | X | | | | | Japanese; Total Ca (food)
van der Pols, 2007^156^ The Boyd Orr Cohort UK (54°–55°N) [8333412] | - Health status; - Mean age (range/SD), yr; - Male (%) | Generally healthy children 7.6 49.5 | - Dietary assessment method; - Internal validation? (y/n) | 7-day household inventory method n | CRC between lowest and highest total calcium intake groups | X | X | X | | | X | Total Ca (food)
Garland, 1985^158^ Western Electric Health Study US (41°N) [2857364] | - Health status; - Mean age (range/SD), yr; - Male (%) | Generally healthy men 48.7 (4.4) 100 | - Dietary assessment method; - Internal validation? (y/n) | 28-day diet histories n | CRC across total calcium intake quartiles | X | X | X | | | X | Total Ca (food)
Nested case-control
Kampman, 1994^159^ The Netherlands Cohort Study Netherlands (52°N) [8205538] | - Health status; - Mean age (range/SD), yr; - Male (%) | Generally healthy men and women nd nd | - Dietary assessment method; - Internal validation? (y/n) | 150-item semi- quantitative FFQ y | CRC across total calcium intake quintiles | X | X | | X | | X | Total Ca (food)

Table 62 Calcium and colorectal cancer: Results of cohort studies

Author Year Study Name Location (Latitude) PMID | Life Stage | Outcome (n/N, Incidence) | Total Ca Intake, mg/day | No. of Cases | No. in Category | Follow up Duration (Time to Dx) | Adjusted RR | 95% CI | P for Trend | Study Quality
Park, 2009^125^ NIH-AARP Diet & Health US (various) [19237724] | Male adult (50–71 y) | CRC (nd) | 526 | nd | nd | 84 mo | 1.0 | Reference | 0.001 | B
Park, 2009^125^ NIH-AARP Diet & Health US (various) [19237724] | Male adult (50–71 y) | CRC (nd) | 498 | nd | nd | 84 mo | 0.89 | 0.80, 0.98^*^ | 0.001 | B
Park, 2009^125^ NIH-AARP Diet & Health US (various) [19237724] | Male adult (50–71 y) | CRC (nd) | 857 | nd | nd | 84 mo | 0.83 | 0.75, 0.93^*^ | 0.001 | B
Park, 2009^125^ NIH-AARP Diet & Health US (various) [19237724] | Male adult (50–71 y) | CRC (nd) | 1073 | nd | nd | 84 mo | 0.87 | 0.78, 0.97^*^ | 0.001 | B
Park, 2009^125^ NIH-AARP Diet & Health US (various) [19237724] | Male adult (50–71 y) | CRC (nd) | 1530 | nd | nd | 84 mo | 0.79 | 0.70, 0.89^*^ | 0.001 | B
Park, 2009^125^ NIH-AARP Diet & Health US (various) [19237724] | Female adult (50–71 y) | CRC (nd) | 494 | nd | nd | 84 mo | 1.0 | Reference | 0.001 | B
Park, 2009^125^ NIH-AARP Diet & Health US (various) [19237724] | Female adult (50–71 y) | CRC (nd) | 717 | nd | nd | 84 mo | 0.87 | 0.75, 1.01 | | B
Park, 2009^125^ NIH-AARP Diet & Health US (various) [19237724] | Female adult (50–71 y) | CRC (nd) | 969 | nd | nd | 84 mo | 0.83 | 0.71, 0.97^*^ | | B
Park, 2009^125^ NIH-AARP Diet & Health US (various) [19237724] | Female adult (50–71 y) | CRC (nd) | 1296 | nd | nd | 84 mo | 0.71 | 0.60, 0.84^*^ | | B
Park, 2009^125^ NIH-AARP Diet & Health US (various) [19237724] | Female adult (50–71 y) | CRC (nd) | 1881 | nd | nd | 84 mo | 0.72 | 0.61, 0.86^*^ | | B
Wu 2002^140^ HPFS: Health Professionals Follow-up Study NHS: Nurses’ Health Study US (various) [11904316] | Male adult (40–75 y) | CRC (nd) | ≤500 | 47 | nd | nd | 1.0 | Reference | 0.17 | B
Wu 2002^140^ HPFS: Health Professionals Follow-up Study NHS: Nurses’ Health Study US (various) [11904316] | Male adult (40–75 y) | CRC (nd) | 501–600 | 48 | nd | nd | 0.69 | 0.46, 1.04 | 0.17 | B
Wu 2002^140^ HPFS: Health Professionals Follow-up Study NHS: Nurses’ Health Study US (various) [11904316] | Male adult (40–75 y) | CRC (nd) | 601–700 | 58 | nd | nd | 0.69 | 0.47, 1.01 | 0.17 | B
Wu 2002^140^ HPFS: Health Professionals Follow-up Study NHS: Nurses’ Health Study US (various) [11904316] | Male adult (40–75 y) | CRC (nd) | 701–800 | 51 | nd | nd | 0.60 | 0.40, 0.90^*^ | 0.17 | B
Wu 2002^140^ HPFS: Health Professionals Follow-up Study NHS: Nurses’ Health Study US (various) [11904316] | Male adult (40–75 y) | CRC (nd) | 801–1000 | 81 | nd | nd | 0.67 | 0.47, 0.97^*^ | 0.17 | B
Wu 2002^140^ HPFS: Health Professionals Follow-up Study NHS: Nurses’ Health Study US (various) [11904316] | Male adult (40–75 y) | CRC (nd) | 1001–1250 | 84 | nd | nd | 0.62 | 0.42, 0.92^*^ | 0.17 | B
Wu 2002^140^ HPFS: Health Professionals Follow-up Study NHS: Nurses’ Health Study US (various) [11904316] | Male adult (40–75 y) | CRC (nd) | >1250 | 60 | nd | nd | 0.64 | 0.43, 0.95^*^ | 0.17 | B
Wu 2002^140^ HPFS: Health Professionals Follow-up Study NHS: Nurses’ Health Study US (various) [11904316] | Female adult (30–55 y) | CRC (nd) | ≤500 | 70 | nd | nd | 1.0 | Reference | 0.35 | B
Wu 2002^140^ HPFS: Health Professionals Follow-up Study NHS: Nurses’ Health Study US (various) [11904316] | Female adult (30–55 y) | CRC (nd) | 501–600 | 79 | nd | nd | 1.19 | 0.86, 1.64 | 0.35 | B
Wu 2002^140^ HPFS: Health Professionals Follow-up Study NHS: Nurses’ Health Study US (various) [11904316] | Female adult (30–55 y) | CRC (nd) | 601–700 | 83 | nd | nd | 1.07 | 0.77, 1.47 | 0.35 | B
Wu 2002^140^ HPFS: Health Professionals Follow-up Study NHS: Nurses’ Health Study US (various) [11904316] | Female adult (30–55 y) | CRC (nd) | 701–800 | 90 | nd | nd | 1.18 | 0.86, 1.63 | 0.35 | B
Wu 2002^140^ HPFS: Health Professionals Follow-up Study NHS: Nurses’ Health Study US (various) [11904316] | Female adult (30–55 y) | CRC (nd) | 801–1000 | 130 | nd | nd | 1.04 | 0.77, 1.40 | 0.35 | B
Wu 2002^140^ HPFS: Health Professionals Follow-up Study NHS: Nurses’ Health Study US (various) [11904316] | Female adult (30–55 y) | CRC (nd) | 1001–1250 | 106 | nd | nd | 1.05 | 0.77, 1.44 | 0.35 | B
Wu 2002^140^ HPFS: Health Professionals Follow-up Study NHS: Nurses’ Health Study US (various) [11904316] | Female adult (30–55 y) | CRC (nd) | >1250 | 68 | nd | nd | 0.94 | 0.66, 1.33 | 0.35 | B
Kesse 2005^141^ Etude Epidémiologique auprès de femmes de l’Education Nationale France (46°N) [15880532] | Female adult (40–65 y) | CRC (nd) | <766.22 | 163 | nd | 82.8 mo | 1.0 | Reference | 0.08 | B
Kesse 2005^141^ Etude Epidémiologique auprès de femmes de l’Education Nationale France (46°N) [15880532] | Female adult (40–65 y) | CRC (nd) | 766.22–962.63 | 154 | nd | 82.8 mo | 0.94 | 0.63, 1.41 | 0.08 | B
Kesse 2005^141^ Etude Epidémiologique auprès de femmes de l’Education Nationale France (46°N) [15880532] | Female adult (40–65 y) | CRC (nd) | 962.63–1201.81 | 150 | nd | 82.8 mo | 0.78 | 0.51, 1.19 | 0.08 | B
Kesse 2005^141^ Etude Epidémiologique auprès de femmes de l’Education Nationale France (46°N) [15880532] | Female adult (40–65 y) | CRC (nd) | > 1201.81 | 131 | nd | 82.8 mo | 0.72 | 0.47, 1.10 | 0.08 | B
Lin 2005^142^ The Women’s Health Study US (various) [15800268] | Female adult (≥45 y) | CRC (41/7691; 0.01) | <614 | 41 | 7691 | 120 mo | 1.0 | Reference | 0.21 | B
Lin 2005^142^ The Women’s Health Study US (various) [15800268] | Female adult (≥45 y) | CRC (nd) | 614–785 | 31 | nd | 120 mo | 0.74 | 0.46, 1.18 | 0.21 | B
Lin 2005^142^ The Women’s Health Study US (various) [15800268] | Female adult (≥45 y) | CRC (0.01) | 785–1016 | 52 | 7690 | 120 mo | 1.19 | 0.78, 1.81 | 0.21 | B
Lin 2005^142^ The Women’s Health Study US (various) [15800268] | Female adult (≥45 y) | CRC (nd) | 1016–1357 | 41 | nd | 120 mo | 0.92 | 0.58, 1.44 | 0.21 | B
Lin 2005^142^ The Women’s Health Study US (various) [15800268] | Female adult (≥45 y) | CRC (58/7690; 0.01) | > 1357 | 58 | 7690 | 120 mo | 1.20 | 0.79, 1.85 | 0.21 | B
Pietinen1999^143^ ATBC Finland (~64°N) [10530608] | Male adult (50–69 y) | CRC (nd) | Median Q1, 856 | 60 | nd | 96 mo | 1.0 | Reference | 0.04 | B
Pietinen1999^143^ ATBC Finland (~64°N) [10530608] | Male adult (50–69 y) | CRC (nd) | Median Q2, 1241 | 41 | nd | 96 mo | 0.7 | 0.5, 1.0 | 0.04 | B
Pietinen1999^143^ ATBC Finland (~64°N) [10530608] | Male adult (50–69 y) | CRC (nd) | Median Q3, 1484 | 45 | nd | 96 mo | 0.7 | 0.5, 1.1 | 0.04 | B
Pietinen1999^143^ ATBC Finland (~64°N) [10530608] | Male adult (50–69 y) | CRC (nd) | Median Q4, 1789 | 39 | nd | 96 mo | 0.6 | 0.6, 0.9^*^ | 0.04 | B
Park 2007^144^ The Multiethnic Cohort Study US (various) [17215380] | Male adult (45–75 y) | CRC (nd) | < 288/1000 kcal | 342 | nd | 87.6 mo | 1.0 | Reference | 0.006 | C
Park 2007^144^ The Multiethnic Cohort Study US (various) [17215380] | Male adult (45–75 y) | CRC (nd) | 288–369/1000 kcal | 271 | nd | 87.6 mo | 1.02 | 0.86, 1.22 | 0.006 | C
Park 2007^144^ The Multiethnic Cohort Study US (various) [17215380] | Male adult (45–75 y) | CRC (nd) | 369–457/1000 kcal | 258 | nd | 87.6 mo | 1.08 | 0.89, 1.31 | 0.006 | C
Park 2007^144^ The Multiethnic Cohort Study US (various) [17215380] | Male adult (45–75 y) | CRC (nd) | 457–611/1000 kcal | 177 | nd | 87.6 mo | 0.85 | 0.68, 1.07 | 0.006 | C
Park 2007^144^ The Multiethnic Cohort Study US (various) [17215380] | Male adult (45–75 y) | CRC (nd) | ≥611/1000 kcal | 90 | nd | 87.6 mo | 0.70 | 0.52, 0.93^*^ | 0.006 | C
Park 2007^144^ The Multiethnic Cohort Study US (various) [17215380] | Female adult (45–75 y) | CRC (nd) | < 288/1000 kcal | 172 | nd | 87.6 mo | 1.0 | Reference | 0.003 | C
Park 2007^144^ The Multiethnic Cohort Study US (various) [17215380] | Female adult (45–75 y) | CRC (nd) | 288–369/1000 kcal | 175 | nd | 87.6 mo | 0.77 | 0.60, 0.97^*^ | 0.003 | C
Park 2007^144^ The Multiethnic Cohort Study US (various) [17215380] | Female adult (45–75 y) | CRC (nd) | 369–457/1000 kcal | 194 | nd | 87.6 mo | 0.76 | 0.60, 0.97^*^ | 0.003 | C
Park 2007^144^ The Multiethnic Cohort Study US (various) [17215380] | Female adult (45–75 y) | CRC (nd) | 457–611/1000 kcal | 197 | nd | 87.6 mo | 0.74 | 0.57, 0.94^*^ | 0.003 | C
Park 2007^144^ The Multiethnic Cohort Study US (various) [17215380] | Female adult (45–75 y) | CRC (nd) | ≥611/1000 kcal | 234 | nd | 87.6 mo | 0.64 | 0.50, 0.83^*^ | 0.003 | C
McCullough 2003^145^ CPS II US (various) [12708719] | Adult (50–74 y) | CRC (nd) | <561 | 156 | nd | nd | 1.0 | Reference | 0.02 | C
McCullough 2003^145^ CPS II US (various) [12708719] | Adult (50–74 y) | CRC (nd) | 561–731 | 165 | nd | nd | 1.05 | 0.84, 1.31 | 0.02 | C
McCullough 2003^145^ CPS II US (various) [12708719] | Adult (50–74 y) | CRC (nd) | 732–925 | 137 | nd | nd | 0.88 | 0.70, 1.12 | 0.02 | C
McCullough 2003^145^ CPS II US (various) [12708719] | Adult (50–74 y) | CRC (nd) | 926–1255 | 108 | nd | nd | 0.72 | 0.56, 0.93^*^ | 0.02 | C
McCullough 2003^145^ CPS II US (various) [12708719] | Adult (50–74 y) | CRC (nd) | >1255 | 117 | nd | nd | 0.87 | 0.67, 1.12 | 0.02 | C
McCullough 2003^145^ CPS II US (various) [12708719] | Male adult (50–74 y) | CRC (nd) | <561 | 89 | nd | nd | 1.0 | Reference | 0.04 | C
McCullough 2003^145^ CPS II US (various) [12708719] | Male adult (50–74 y) | CRC (nd) | 561–731 | 106 | nd | nd | 1.01 | 0.76, 1.34 | 0.04 | C
McCullough 2003^145^ CPS II US (various) [12708719] | Male adult (50–74 y) | CRC (nd) | 732–925 | 98 | nd | nd | 0.93 | 0.70, 1.25 | 0.04 | C
McCullough 2003^145^ CPS II US (various) [12708719] | Male adult (50–74 y) | CRC (nd) | 926–1255 | 70 | nd | nd | 0.71 | 0.52, 0.98^*^ | 0.04 | C
McCullough 2003^145^ CPS II US (various) [12708719] | Male adult (50–74 y) | CRC (nd) | >1255 | 58 | nd | nd | 0.82 | 0.58, 1.16 | 0.04 | C
McCullough 2003^145^ CPS II US (various) [12708719] | Male adult (50–74 y) | Colon cancer (nd) | <561 | 64 | nd | nd | 1.0 | Reference | 0.02 | C
McCullough 2003^145^ CPS II US (various) [12708719] | Male adult (50–74 y) | Colon cancer (nd) | 561–731 | 82 | nd | nd | 1.08 | 0.77, 1.50^*^ | 0.02 | C
McCullough 2003^145^ CPS II US (various) [12708719] | Male adult (50–74 y) | Colon cancer (nd) | 732–925 | 67 | nd | nd | 0.89 | 0.63, 1.27^*^ | 0.02 | C
McCullough 2003^145^ CPS II US (various) [12708719] | Male adult (50–74 y) | Colon cancer (nd) Colon cancer (nd) | 926–1255 >1255 | 51 38 | nd nd | nd nd | 0.72 0.74 | 0.49, 1.05^*^ 0.49, 1.12^*^ | 0.02 | C
| | Rectal cancer (nd) | <561 | 23 | nd | nd | 1.0 | Reference | 0.71
| | Rectal cancer (nd) | 561–731 | 22 | nd | nd | 0.78 | 0.43, 1.41 | 0.71
| | Rectal cancer (nd) | 732–925 | 29 | nd | nd | 1.02 | 0.58, 1.79 | 0.71
| | Rectal cancer (nd) | 926–1255 | 16 | nd | nd | 0.60 | 0.31, 1.16 | 0.71
| | Rectal cancer (nd) | >1255 | 19 | nd | nd | 1.01 | 0.53, 1.93 | 0.71
| Female adult (50–74 y) | CRC (nd) | <561 | 67 | nd | nd | 1.0 | Reference | 0.31
| Female adult (50–74 y) | CRC (nd) | 561–731 | 59 | nd | nd | 1.16 | 0.82, 1.66 | 0.31
| Female adult (50–74 y) | CRC (nd) | 732–925 | 39 | nd | nd | 0.80 | 0.54, 1.21 | 0.31
| Female adult (50–74 y) | CRC (nd) | 926–1255 | 38 | nd | nd | 0.78 | 0.51, 1.18 | 0.31
| Female adult (50–74 y) | CRC (nd) | >1255 | 59 | nd | nd | 0.94 | 0.63, 1.39 | 0.31
Shin 2006^149^ Shanghai Women’s Health Study China (31°N) [17019716] | Female adult (40–70) | CRC (nd) | ≤291.9 | nd | nd | Median, 68.9 mo | 1.0 | Reference | 0.48 | C
Shin 2006^149^ Shanghai Women’s Health Study China (31°N) [17019716] | Female adult (40–70) | CRC (nd) | ≤389.9 | nd | nd | Median, 68.9 mo | 1.0 | 0.7, 1.4 | 0.48 | C
Shin 2006^149^ Shanghai Women’s Health Study China (31°N) [17019716] | Female adult (40–70) | CRC (nd) | ≤488.2 | nd | nd | Median, 68.9 mo | 1.0 | 0.7, 1.4 | 0.48 | C
Shin 2006^149^ Shanghai Women’s Health Study China (31°N) [17019716] | Female adult (40–70) | CRC (nd) | ≤610.8 | nd | nd | Median, 68.9 mo | 0.9 | 0.6, 1.3 | 0.48 | C
Shin 2006^149^ Shanghai Women’s Health Study China (31°N) [17019716] | Female adult (40–70) | CRC (nd) | > 610.8 | nd | nd | Median, 68.9 mo | 0.9 | 0.6, 1.3 | 0.48 | C
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (≥76 y) | CRC (nd) | Mean (SD) Q1, 486 (79) | 156 | nd | 135.6 mo | 1.0 | Reference | 0.02 | C
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (≥76 y) | CRC (nd) | Mean (SD) Q2, 631 (34) | 149 | nd | 135.6 mo | 0.97 | 0.77, 1.21 | 0.02 | C
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (≥76 y) | CRC (nd) | Mean (SD) Q3, 747 (37) | 145 | nd | 135.6 mo | 0.95 | 0.75, 1.20 | 0.02 | C
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (≥76 y) | CRC (nd) | Mean (SD) Q4, 914 (136) | 122 | nd | 135.6 mo | 0.72 | 0.56, 0.93* | 0.02 | C
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (≥76 y) | Colon cancer (nd) | Mean (SD) Q1, 486 (79) | 100 | nd | 135.6 mo | 1.0 | Reference | 0.06
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (≥76 y) | Colon cancer (nd) | Mean (SD) Q2, 631 (34) | 97 | nd | 135.6 mo | 0.97 | 0.74, 1.30 | 0.06
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (≥76 y) | Colon cancer (nd) | Mean (SD) Q3, 747 (37) | 92 | nd | 135.6 mo | 0.93 | 0.70, 1.24 | 0.06
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (≥76 y) | Colon cancer (nd) | Mean (SD) Q4, 914 (136) | 82 | nd | 135.6 mo | 0.74 | 0.54, 1.01 | 0.06
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (≥76 y) | Rectal cancer (nd) | Mean (SD) Q1, 486 (79) | 55 | nd | 135.6 mo | 1.0 | Reference | 0.12
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (≥76 y) | Rectal cancer (nd) | Mean (SD) Q2, 631 (34) | 48 | nd | 135.6 mo | 0.89 | 0.60, 1.32 | 0.12
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (≥76 y) | Rectal cancer (nd) | Mean (SD) Q3, 747 (37) | 49 | nd | 135.6 mo | 0.94 | 0.63, 1.39 | 0.12
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (≥76 y) | Rectal cancer (nd) | Mean (SD) Q4, 914 (136) | 39 | nd | 135.6 mo | 0.70 | 0.45, 1.09 | 0.12
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (< 55 y) | CRC (nd) | 176–568 | nd | nd | 135.6 mo | 1.0 | Reference | 0.77
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (< 55 y) | CRC (nd) | 568–688 | nd | nd | 135.6 mo | 1.06 | 0.68, 1.66 | 0.77
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (< 55 y) | CRC (nd) | 688–816 | nd | nd | 135.6 mo | 1.11 | 0.71, 1.73 | 0.77
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (< 55 y) | CRC (nd) | 816–1300 | nd | nd | 135.6 mo | 0.91 | 0.56, 1.48 | 0.77
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (≥55 y) | CRC (nd) | 176–568 | nd | nd | 135.6 mo | 1.0 | Reference | 0.008
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (≥55 y) | CRC (nd) | 568–688 | nd | nd | 135.6 mo | 0.93 | 0.71, 1.21 | 0.008
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (≥55 y) | CRC (nd) | 688–816 | nd | nd | 135.6 mo | 0.89 | 0.68, 1.17 | 0.008
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (≥55 y) | CRC (nd) | 816–1300 | nd | nd | 135.6 mo | 0.66 | 0.49, 0.89* | 0.008
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (< 55 y) | Colon cancer (nd) | 176–568 | nd | nd | 135.6 mo | 1.0 | Reference | 0.92
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (< 55 y) | Colon cancer (nd) | 568–688 | nd | nd | 135.6 mo | 1.32 | 0.75 2.30 | 0.92
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (< 55 y) | Colon cancer (nd) | 688–816 | nd | nd | 135.6 mo | 1.02 | 0.55, 1.85 | 0.92
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (< 55 y) | Colon cancer (nd) | 816–1300 | nd | nd | 135.6 mo | 1.11 | 0.60, 2.05 | 0.92
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (≥55 y) | Colon cancer (nd) | 176–568 | nd | nd | 135.6 mo | 1.0 | Reference | 0.02
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (≥55 y) | Colon cancer (nd) | 568–688 | nd | nd | 135.6 mo | 0.89 | 0.64, 1.23 | 0.02
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (≥55 y) | Colon cancer (nd) | 688–816 | nd | nd | 135.6 mo | 0.91 | 0.65, 1.26 | 0.02
Terry 2002^146^ Swedish Mammography Screening Cohort Sweden (59°N) [12467133] | Female adult (≥55 y) | Colon cancer (nd) | 816–1300 | nd | nd | 135.6 mo | 0.64 | 0.44, 0.92* | 0.02
| Female adult (< 55 y) | Rectal cancer (nd) | 176–568 | nd | nd | 135.6 mo | 1.0 | Reference | 0.75
| Female adult (< 55 y) | Rectal cancer (nd) | 568–688 | nd | nd | 135.6 mo | 0.33 | 0.34, 1.59 | 0.75
| Female adult (< 55 y) | Rectal cancer (nd) | 688–816 | nd | nd | 135.6 mo | 1.30 | 0.66, 2.56 | 0.75
| Female adult (< 55 y) | Rectal cancer (nd) | 816–1300 | nd | nd | 135.6 mo | 0.70 | 0.31, 1.62 | 0.75
| Female adult (≥55 y) | Rectal cancer (nd) | 176–568 | nd | nd | 135.6 mo | 1.0 | Reference | 0.15
| Female adult (≥55 y) | Rectal cancer (nd) | 568–688 | nd | nd | 135.6 mo | 0.96 | 0.61, 1.52 | 0.15
| Female adult (≥55 y) | Rectal cancer (nd) | 688–816 | nd | nd | 135.6 mo | 0.79 | 0.48, 1.29 | 0.15
| Female adult (≥55 y) | Rectal cancer (nd) | 816–1300 | nd | nd | 135.6 mo | 0.70 | 0.42, 1.19 | 0.15
Gaard 1996^153^ Norway (60°–69°N) [9061275] | Male adult (20–53 y) | Colon cancer (nd) | <758 | 22 | nd | 134.4 mo | 1.0 | Reference | 0.15 | C
Gaard 1996^153^ Norway (60°–69°N) [9061275] | Male adult (20–53 y) | Colon cancer (nd) | 759–912 | 24 | nd | 134.4 mo | 1.02 | 0.57, 1.83 | 0.15 | C
Gaard 1996^153^ Norway (60°–69°N) [9061275] | Male adult (20–53 y) | Colon cancer (nd) | 913–1066 | 24 | nd | 134.4 mo | 1.04 | 0.58, 1.86 | 0.15 | C
Gaard 1996^153^ Norway (60°–69°N) [9061275] | Male adult (20–53 y) | Colon cancer (nd) | >1067 | 13 | nd | 134.4 mo | 0.57 | 0.29, 1.13 | 0.15 | C
Gaard 1996^153^ Norway (60°–69°N) [9061275] | Female adult (20–53 y) | Colon cancer (nd) | <527 | 15 | nd | 134.4 mo | 1.0 | Reference | 0.94 | C
Gaard 1996^153^ Norway (60°–69°N) [9061275] | Female adult (20–53 y) | Colon cancer (nd) | 528–628 | 20 | nd | 134.4 mo | 1.25 | 0.63, 2.46 | 0.94 | C
Gaard 1996^153^ Norway (60°–69°N) [9061275] | Female adult (20–53 y) | Colon cancer (nd) | 629–743 | 7 | nd | 134.4 mo | 0.46 | 0.19, 1.12 | 0.94 | C
Gaard 1996^153^ Norway (60°–69°N) [9061275] | Female adult (20–53 y) | Colon cancer (nd) | >744 | 18 | nd | 134.4 mo | 1.20 | 0.60, 2.39 | 0.94 | C
Flood 2005^147^) The Breast Cancer Detection Demonstration Project (BCDDP)) US (various)) [15668485] | Female adult (nd) | CRC (nd) | <472 | 102 | nd | 17 mo | 1.0 | Reference | 0.02 | C
Flood 2005^147^) The Breast Cancer Detection Demonstration Project (BCDDP)) US (various)) [15668485] | Female adult (nd) | CRC (nd) | 472–635 | 110 | nd | 17 mo | 1.03 | 0.79, 1.35 | 0.02 | C
Flood 2005^147^) The Breast Cancer Detection Demonstration Project (BCDDP)) US (various)) [15668485] | Female adult (nd) | CRC (nd) | 636–844 | 86 | nd | 17 mo | 0.80 | 0.60, 1.06 | 0.02 | C
Flood 2005^147^) The Breast Cancer Detection Demonstration Project (BCDDP)) US (various)) [15668485] | Female adult (nd) | CRC (nd) | 845–1270 | 106 | nd | 17 mo | 0.96 | 0.73, 1.26 | 0.02 | C
Flood 2005^147^) The Breast Cancer Detection Demonstration Project (BCDDP)) US (various)) [15668485] | Female adult (nd) | CRC (nd) | >1270 | 80 | nd | 17 mo | 0.74 | 0.55, 0.99* | 0.02 | C
Flood 2005^147^) The Breast Cancer Detection Demonstration Project (BCDDP)) US (various)) [15668485] | Female adult (nd) | Colon cancer (nd) | <472 | nd | nd | 17 mo | 1.0 | Reference | 0.10 | C
Flood 2005^147^) The Breast Cancer Detection Demonstration Project (BCDDP)) US (various)) [15668485] | Female adult (nd) | Colon cancer (nd) | 472–635 | nd | nd | 17 mo | 0.84 | 0.59, 1.18 | 0.10 | C
Flood 2005^147^) The Breast Cancer Detection Demonstration Project (BCDDP)) US (various)) [15668485] | Female adult (nd) | Colon cancer (nd) | 636–844 | nd | nd | 17 mo | 0.66 | 0.46, 0.96* | 0.10 | C
Flood 2005^147^) The Breast Cancer Detection Demonstration Project (BCDDP)) US (various)) [15668485] | Female adult (nd) | Colon cancer (nd) | 845–1270 | nd | nd | 17 mo | 0.78 | 0.55, 1.11 | 0.10 | C
Flood 2005^147^) The Breast Cancer Detection Demonstration Project (BCDDP)) US (various)) [15668485] | Female adult (nd) | Colon cancer (nd) | >1270 | nd | nd | 17 mo | 0.69 | 0.48, 0.99* | 0.10 | C
Flood 2005^147^) The Breast Cancer Detection Demonstration Project (BCDDP)) US (various)) [15668485] | Female adult (nd) | Rectal cancer (nd) | <472 | nd | nd | 17 mo | 1.0 | Reference | 0.30 | C
Flood 2005^147^) The Breast Cancer Detection Demonstration Project (BCDDP)) US (various)) [15668485] | Female adult (nd) | Rectal cancer (nd) | 472–635 | nd | nd | 17 mo | 1.19 | 0.57, 2.48 | 0.30 | C
Flood 2005^147^) The Breast Cancer Detection Demonstration Project (BCDDP)) US (various)) [15668485] | Female adult (nd) | Rectal cancer (nd) | 636–844 | nd | nd | 17 mo | 1.10 | 0.52, 2.32 | 0.30 | C
Flood 2005^147^) The Breast Cancer Detection Demonstration Project (BCDDP)) US (various)) [15668485] | Female adult (nd) | Rectal cancer (nd) | 845–270 | nd | nd | 17 mo | 1.23 | 0.60, 2.53 | 0.30 | C
Flood 2005^147^) The Breast Cancer Detection Demonstration Project (BCDDP)) US (various)) [15668485] | Female adult (nd) | Rectal cancer (nd) | >1270 | nd | nd | 17 mo | 0.93 | 0.43, 2.01 | 0.30 | C
Larsson 2006^148^ The Cohort of Swedish Men Sweden (59°N) [16522915] | Male adult (45–79 y) | CRC (111/11,341; 0.011) | <956 | 127 | 11,348 | 80.4 mo | 1.0 | Reference | 0.01 | C
Larsson 2006^148^ The Cohort of Swedish Men Sweden (59°N) [16522915] | Male adult (45–79 y) | CRC (107/11295; 0.010) | 956–1179 | 111 | 11,341 | 80.4 mo | 0.80 | 0.61, 1.04 | 0.01 | C
Larsson 2006^148^ The Cohort of Swedish Men Sweden (59°N) [16522915] | Male adult (45–79 y) | CRC (104/11,322; 0.009) | 1180–1444 | 107 | 11,295 | 80.4 mo | 0.73 | 0.56, 0.96* | 0.01 | C
Larsson 2006^148^ The Cohort of Swedish Men Sweden (59°N) [16522915] | Male adult (45–79 y) | CRC (67/11,322; 0.009) | >1445 | 104 | 11,322 | 80.4 mo | 0.68 | 0.51, 0.91* | 0.01 | C
Larsson 2006^148^ The Cohort of Swedish Men Sweden (59°N) [16522915] | Male adult (45–79 y) | Colon cancer (77/11,348; 0.006) | <956 | 67 | 11,322 | 80.4 mo | 0.72 | 0.50, 1.04 | 0.15 | C
Larsson 2006^148^ The Cohort of Swedish Men Sweden (59°N) [16522915] | Male adult (45–79 y) | Colon cancer (70/11,295; 0.007) | 956–1179 | 77 | 11,348 | 80.4 mo | 1.0 | Reference | 0.15 | C
Larsson 2006^148^ The Cohort of Swedish Men Sweden (59°N) [16522915] | Male adult (45–79 y) | Colon cancer (67/11,322; 0.006) | 1180–1444 | 70 | 11,295 | 80.4 mo | 0.80 | 0.57, 1.12 | 0.15 | C
Larsson 2006^148^ The Cohort of Swedish Men Sweden (59°N) [16522915] | Male adult (45–79 y) | Colon cancer (50/11,348; 0.006) | >1445 | 67 | 11,322 | 80.4 mo | 0.72 | 0.50, 1.04 | 0.15 | C
Larsson 2006^148^ The Cohort of Swedish Men Sweden (59°N) [16522915] | Male adult (45–79 y) | Rectal cancer (49/11,341; 0.004) | <956 | 50 | 11,348 | 80.4 mo | 1.0 | Reference | 0.02 | C
Larsson 2006^148^ The Cohort of Swedish Men Sweden (59°N) [16522915] | Male adult (45–79 y) | Rectal cancer (37/11,295; 0.004) | 956–179 | 49 | 11,341 | 80.4 mo | 0.91 | 0.61, 1.37 | 0.02 | C
Larsson 2006^148^ The Cohort of Swedish Men Sweden (59°N) [16522915] | Male adult (45–79 y) | Rectal cancer (37/11,322; 0.003) | 1180–444 | 37 | 11,295 | 80.4 mo | 0.63 | 0.40, 0.98* | 0.02 | C
Larsson 2006^148^ The Cohort of Swedish Men Sweden (59°N) [16522915] | Male adult (45–79 y) | Rectal cancer (37/11,322; 0.003) | >1445 | 37 | 11,322 | 80.4 mo | 0.61 | 0.38, 0.98* | 0.02 | C
Bostick 1993^150^ Iowa Women’s Health Study US (40°N) [8333412] | Female adult (55–69 y) | Colon cancer (nd) | <629 | 54 | nd | nd | 1.0 | Reference | 0.22
Bostick 1993^150^ Iowa Women’s Health Study US (40°N) [8333412] | Female adult (55–69 y) | Colon cancer (nd) | 629–896 | 44 | nd | nd | 0.89 | 0.59, 1.33 | 0.22
Bostick 1993^150^ Iowa Women’s Health Study US (40°N) [8333412] | Female adult (55–69 y) | Colon cancer (nd) | 897–1188 | 42 | nd | nd | 0.88 | 0.58, 1.33 | 0.22
Bostick 1993^150^ Iowa Women’s Health Study US (40°N) [8333412] | Female adult (55–69 y) | Colon cancer (nd) | 1189–1547 | 44 | nd | nd | 0.97 | 0.63, 1.50 | 0.22
Bostick 1993^150^ Iowa Women’s Health Study US (40°N) [8333412] | Female adult (55–69 y) | Colon cancer (nd) | >1548 | 28 | nd | nd | 0.68 | 0.41, 1.11 | 0.22
Zheng 1998^152^ Iowa Women’s Health Study US (40°N) [9521437] | Female adult, (55–69 y) | Rectal cancer (nd) | <800.8 | 56 | nd | 108 mo | 1.0 | Reference | 0.02 | C
Zheng 1998^152^ Iowa Women’s Health Study US (40°N) [9521437] | Female adult, (55–69 y) | Rectal cancer (nd) | 800.8–1278.7 | 52 | nd | 108 mo | 0.90 | 0.61, 1.33 | 0.02 | C
Zheng 1998^152^ Iowa Women’s Health Study US (40°N) [9521437] | Female adult, (55–69 y) | Rectal cancer (nd) | ≥1278.7 | 36 | nd | 108 mo | 0.59 | 0.37, 0.94* | 0.02 | C
Kato 1997^155^ New York University Women’s Health Study US (various) [9343837] | Female adult (34–65 y) | CRC (nd) | Lowest, Q1 (nd) | nd | nd | 85.2 mo | 1.0 | Reference | 0.18 | C
Kato 1997^155^ New York University Women’s Health Study US (various) [9343837] | Female adult (34–65 y) | CRC (nd) | Q2 (nd) | nd | nd | 85.2 mo | 1.15 | 0.67, 1.95 | 0.18 | C
Kato 1997^155^ New York University Women’s Health Study US (various) [9343837] | Female adult (34–65 y) | CRC (nd) | Q3 (nd) | nd | nd | 85.2 mo | 0.90 | 0.52, 1.57 | 0.18 | C
Kato 1997^155^ New York University Women’s Health Study US (various) [9343837] | Female adult (34–65 y) | CRC (nd) | Highest Q4 (nd) | nd | nd | 85.2 mo | 0.71 | 0.39, 1.28 | 0.18 | C
Wu 1987^154^ US (21°N) [3620314] | Male adult (nd) | CRC (nd) | Low tertile (nd) | nd | nd | nd | 1.0 | Reference | ns | C
Wu 1987^154^ US (21°N) [3620314] | Male adult (nd) | CRC (nd) | Medium tertile (nd) | nd | nd | nd | 1.19 | 0.6, 2.2 | ns | C
Wu 1987^154^ US (21°N) [3620314] | Male adult (nd) | CRC (nd) | High tertile(nd) | nd | nd | nd | 0.86 | 0.4, 1.7 | ns | C
Wu 1987^154^ US (21°N) [3620314] | Female adult (nd) | CRC (nd) | Low tertile (nd) | nd | nd | nd | 1.0 | Reference | ns | C
Wu 1987^154^ US (21°N) [3620314] | Female adult (nd) | CRC (nd) | Medium tertile (nd) | nd | nd | nd | 0.9 | 0.5, 1.6 | ns | C
Wu 1987^154^ US (21°N) [3620314] | Female adult (nd) | CRC (nd) | High tertile (nd) | nd | nd | nd | 0.89 | 0.5, 1.6 | ns | C
Jarvinen 2001^157^ Finland (64°N) [11641750] | Adolescent and adult (> 15 y) | CRC (nd) | Male: <1178.2 Female: <862.5 | 20 | nd | 235.2 mo | 1.0 | Reference | 0.97 | C
Jarvinen 2001^157^ Finland (64°N) [11641750] | Adolescent and adult (> 15 y) | CRC (nd) | Male: 1178.2–1557.1 Female: 862.5–1110.7 | 19 | nd | 235.2 mo | 1.17 | 0.60, 2.27 | 0.97 | C
Jarvinen 2001^157^ Finland (64°N) [11641750] | Adolescent and adult (> 15 y) | CRC (nd) | Male: 1557.2–1953.2 Female: 1110.8–1416.6 | 18 | nd | 235.2 mo | 1.37 | 0.67, 2.81 | 0.97 | C
Jarvinen 2001^157^ Finland (64°N) [11641750] | Adolescent and adult (> 15 y) | CRC (nd) | Male: >1953.3 Female: >1416.7 | 15 | nd | 235.2 mo | 1.43 | 0.61, 3.39 | 0.97 | C
Jarvinen 2001^157^ Finland (64°N) [11641750] | Adolescent and adult (> 15 y) | Colon cancer (nd) | Male: <1178.2 Female: <862.5 | 10 | nd | 235.2 mo | 1.0 | Reference | 0.17 | C
Jarvinen 2001^157^ Finland (64°N) [11641750] | Adolescent and adult (> 15 y) | Colon cancer (nd) | Male: 1178.2–1557.1 Female: 862.5–1110.7 | 14 | nd | 235.2 mo | 1.44 | 0.61, 3.39 | 0.17 | C
Jarvinen 2001^157^ Finland (64°N) [11641750] | Adolescent and adult (> 15 y) | Colon cancer (nd) | Male: 1557.2–1953.2 Female: 1110.8–1416.6 | 9 | nd | 235.2 mo | 1.04 | 0.38, 2.83 | 0.17 | C
Jarvinen 2001^157^ Finland (64°N) [11641750] | Adolescent and adult (> 15 y) | Colon cancer (nd) | Male: >1953.3 Female: >1416.7 | 5 | nd | 235.2 mo | 0.63 | 0.17, 2.35 | 0.17 | C
Jarvinen 2001^157^ Finland (64°N) [11641750] | Adolescent and adult (> 15 y) | Rectal cancer(nd) | Male: <1178.2 Female: <862.5 | 10 | nd | 235.2 mo | 1.0 | Reference | 0.19
Jarvinen 2001^157^ Finland (64°N) [11641750] | Adolescent and adult (> 15 y) | Rectal cancer(nd) | Male: 1178.2–1557.1 Female: 862.5–1110.7 | 5 | nd | 235.2 mo | 0.77 | 0.25, 2.37 | 0.19
Jarvinen 2001^157^ Finland (64°N) [11641750] | Adolescent and adult (> 15 y) | Rectal cancer(nd) | Male: 1557.2–1953.2 Female: 1110.8–1416.6 | 9 | nd | 235.2 mo | 1.88 | 0.67, 5.30 | 0.19
Jarvinen 2001^157^ Finland (64°N) [11641750] | Adolescent and adult (> 15 y) | Rectal cancer(nd) | Male: > 1953.3 Female: > 1416.7 | 10 | nd | 235.2 mo | 3.01 | 0.93, 9.73 | 0.19
Stemmermann 1990^151^ Japan Hawaii Cancer Study US (21°N) [2311461] | Male adult (nd) | Colon cancer (74/2466; 0.02) | Low (nd) | 74 | 2466 | nd | 1.3 | 0.9, 1.8 | 0.16 | C
Stemmermann 1990^151^ Japan Hawaii Cancer Study US (21°N) [2311461] | Male adult (nd) | Colon cancer (57/2456; 0.02) | Medium (nd) | 57 | 2456 | nd | 1.0 | 0.7, 1.4 | 0.16 | C
Stemmermann 1990^151^ Japan Hawaii Cancer Study US (21°N) [2311461] | Male adult (nd) | Colon cancer (58/2461; 0.03) | High (nd) | 58 | 2461 | nd | 1.0 | Reference | 0.16 | C
van der Pols 2007^156^ The Boyd Orr Cohort UK (54°–55°N) [8333412] | Children (IQR 4–11 y) | CRC (nd) | Lowest Q1, (nd) | nd | nd | nd | 1.0 | Reference | 0.18 | C
van der Pols 2007^156^ The Boyd Orr Cohort UK (54°–55°N) [8333412] | Children (IQR 4–11 y) | CRC (nd) | Highest Q4, (nd) | nd | nd | nd | 1.91 | 0.84, 4.32 | 0.18 | C
Garland 1985^158^ Western Electric Health Study US (41°N) [2857364] | Male adult (40–55 y) | CRC (19/488; 0.04) | 102–241/1000 kcal | 19 | 488 | nd | Nd | nd | nd | C
Garland 1985^158^ Western Electric Health Study US (41°N) [2857364] | Male adult (40–55 y) | CRC (12/489; 0.02) | 242–306/1000kcal | 12 | 489 | nd | Nd | nd | nd | C
Garland 1985^158^ Western Electric Health Study US (41°N) [2857364] | Male adult (40–55 y) | CRC (12/489; 0.02) | 307–383/1000 kcal | 12 | 489 | nd | nd | nd | nd | C
Garland 1985^158^ Western Electric Health Study US (41°N) [2857364] | Male adult (40–55 y) | CRC (6/458; 0.01) | 384–906/1000 kcal | 6 | 458 | nd | nd | nd | nd | C

Table 63 Calcium and colorectal cancer: Results of nested case-control studies

Author Year Study Name Location (Latitude) PMID | Life Stage | Outcome (n/N, Incidence) | Total Ca Intake, mg/day | No. of Cases | No. in Category | Follow up Duration (Time to Dx) | Adjusted RR | 95% CI | P for Trend | Study Quality
Kampman 1994^159^ The Netherlands Cohort Study Netherlands (52°N) [8205538] | Adult (55–69 y) | CRC (443/3111, 0.14) | Median Q1, 596 | 98 | 623 | 39.6 mo | 1.0 | Reference | 0.89 | B
Kampman 1994^159^ The Netherlands Cohort Study Netherlands (52°N) [8205538] | Adult (55–69 y) | CRC (443/3111, 0.14) | Median Q2, 768 | 89 | 619 | 39.6 mo | 0.83 | 0.58, 1.22 | 0.89 | B
Kampman 1994^159^ The Netherlands Cohort Study Netherlands (52°N) [8205538] | Adult (55–69 y) | CRC (443/3111, 0.14) | Median Q3, 893 | 87 | 622 | 39.6 mo | 0.96 | 0.67, 1.39 | 0.89 | B
Kampman 1994^159^ The Netherlands Cohort Study Netherlands (52°N) [8205538] | Adult (55–69 y) | CRC (443/3111, 0.14) | Median Q4, 1032 | 81 | 627 | 39.6 mo | 0.93 | 0.64, 1.36 | 0.89 | B
Kampman 1994^159^ The Netherlands Cohort Study Netherlands (52°N) [8205538] | Adult (55–69 y) | CRC (443/3111, 0.14) | Median Q5, 1288 | 88 | 620 | 39.6 mo | 0.92 | 0.64, 1.34 | 0.89 | B

Figure 14 Colorectal cancer risk in both sexes stratified by calcium intake

Figure 15 Colorectal cancer risk in men stratified by calcium intake

Figure 16 Colorectal cancer risk in women stratified by calcium intake

Figure 17 Colon cancer risk stratified by calcium intake

Figure 18 Rectal cancer risk stratified by calcium intake

One systematic review of two RCTs of supplemental calcium on prevention of recurrent colorectal adenoma comprising 1346 adults (mean age 59 to 61 years) examined colorectal cancer incidence.139 A fixed-effects model meta-analysis found no significant difference in colorectal cancer incidence between supplemental calcium and no supplements. This meta-analysis is considered inconclusive because only 5 colorectal cancer cases were diagnosed during the study period.

Nineteen cohort studies in 20 publications125,140–158 and one nested case-control study159 evaluated the association between calcium intake and colorectal, colon, or rectal cancer. Sample sizes ranged from 1954 to 492,810. Half of the studies were conducted in the US (latitude ranged from 21° N to 54° N),125,140,142,144,145,147,150–152,154,155,158 one study was conducted in China (latitude 31° N),149 and the rest were conducted in Europe including France (latitude 46° N),141 the Netherlands (latitude 52° N),159 the United Kingdom (latitude ranged between 54° N and 55° N),156 and Scandinavia (latitude ranged between 59° N and 69° N).143,146,148,153,157 For colorectal cancer, the incidence ranged from 0.003 to 0.025 for cohorts, while in the nested case-control study, the colorectal cancer incidence was 0.142; for colon cancer, the incidence ranged from 0.003 to 0.024; and for rectal cancer, the incidence ranged from 0.003 to 0.004. The participants’ mean age ranged from 7.6 to 61.9 years. Average followup ranged from 1.4 to 19.6 years. Only one study reported that exposure assessors were blinded to outcome.154 No studies mentioned that outcome assessors were blinded to exposure. None of the studies reported power calculations. The majority of the studies evaluated the potential effect of various factors besides calcium on colorectal cancer. All performed analyses adjusted at least for age. Except for four studies151,156–158 that used dietary history, all other studies used a food frequency questionnaire to assess dietary intake. More than half of the studies did not confirm all or part of cancer cases with pathology reports. Six studies125,140–143,159 were rated B, and 15 publications144–158 were rated C for methodological quality.

Findings by age, sex and/or ethnicity

One cohort study analyzed a total of 4374 children (IQR 4–11 years old) living in the United Kingdom. It found no significant association between total calcium intake and colorectal cancer in these children after 65 years of followup.156

One cohort study analyzed a total of 127,749 adults aged between 50 and 74 years old living in US. It found an inverse association between total calcium intake and colorectal cancer.145 However, another cohort study and one nested case-control study did not find such an association.157,159 The only cohort study that analyzed subjects older than 15 years did not find a significant association between total calcium intake and colon cancer as well as rectal cancer in subgroup analyses.157 Out of seven cohort studies125,140,143–145,148,154 that analyzed male adults older than 40 years living in US, or Scandinavia, five125,143–145,148 found an inverse association between total calcium intake and colorectal cancer. Out of eleven cohort studies125,140–142,144–147,149,154,155 that analyzed women, four125,144,146,147 found an inverse association between total calcium intake and colorectal cancer.

Out of four cohort studies145,148,151,153 that analyzed men, one145 found an inverse association between total calcium intake and colon cancer in a subgroup analysis. Out of four cohort studies146,147,150,153 that analyzed women, none found an association between total calcium intake and colon cancer. For rectal cancer, one148 of two145,148 studies that analyzed men and one152 of three146,147,152 studies that analyzed women found an inverse association between total calcium intake and rectal cancer.148,152

One cohort study in the US found an inverse association between total calcium intake and colorectal cancer in a subgroup analysis of Japanese Americans aged 45 to 75 years, and a borderline inverse association in Caucasians of the same age range; however, the same cohort study did not find any significant association in subgroup analyses of African Americans, Native Hawaiians, and Latinos.144 Another cohort study in the US that recruited only Japanese American men living in Hawaii did not find an association between total calcium intake and colon cancer.151 One cohort study did not find any association in Chinese women (aged 40 to 70 years) living in Shanghai,149

Findings by life stage

- 0–6 mo No data
- 7 mo–2 y No data
- 3–8 y One study that followed up children with an interquartile range of age of 4 to 11 years for 65 years found no significant association between total calcium intake at baseline and the risk of colorectal cancer.
- 9–18 y Three studies included some children and/or adolescents in this life stage, but no studies adequately evaluated this life stage.
- 19–50 y Four studies included people with a mean or median age ranging from 39 to 50 years. No significant association was found between total calcium intake and colorectal cancer risk. Ten additional studies may have included participants in this life stage; however in these studies, no conclusions are possible for the subgroup in this life stage.
- 51–70 y One inconclusive meta-analysis of 2 RCTs in adults with previous adenomatous polyps (mean age 59–61 years) found no significant difference in colorectal cancer incidence between those who were and those who were not supplemented at followup. Ten studies included people with a mean or median age ranged from 53 to 69 years. An association between higher total calcium intake and lower colorectal cancer risk was found in three studies in men and two studies in women. Another study of women found an association between higher total calcium intake and lower rectal cancer risk. Ten additional studies may also have included participants in this life stage An association between higher total calcium intake and lower colorectal cancer risk was found in two studies in men and two studies in women. However in these studies, the results are inconclusive for the subgroup in this life stage.
- 71+ One study that specifically included people in the retirement community found no association between total calcium intake and colorectal cancer risk. Nine additional studies may have also recruited participants in this life stage; however in these studies, no conclusions are possible for the subgroup in this life stage.
- Postmenopause One study focused on postmenopausal women. This study found an association between higher calcium intake and lower rectal cancer risk. However, it did not find any association for colon cancer risk.
- Pregnant & lactating women No data

#### Colorectal adenoma

Synopsis

This synopsis is based on one systematic review, two comparative trials (one post hoc followup study of an RCT and one nonrandomized trial), and four cohort studies. The systematic review that included two RCTs which evaluated high risk population for the prevention of colorectal adenoma recurrence showed a reduction in the risk of colorectal adenoma with calcium supplementation (OR 0.74, 95 percent CI 0.58, 0.95; P=0.02). The B quality long-term followup study of an RCT of calcium supplementation (1200 mg/d) versus placebo in healthy adults showed no significant difference in the risk of recurrence of colorectal adenoma. The nonrandomized comparative trial (methodological quality C) also found a significant reduction in adenoma recurrence risk among healthy adults who received calcium supplementation. Among four cohort studies (methodological quality B), two found an inverse association between total calcium intake and the risk of colorectal adenoma, while the others found no significant association.

Detailed presentation

(Tables 64, 65, 66, 67 & 68; Figure 19)

Table 64 Calcium and colorectal adenoma: Characteristics of interventional studies

Author, Year Trial/Cohort Name Country (Latitude) [Pubmed ID] | Population | | Vit D & Ca Background Diets | Interventions | Compliance | Comments
RCTs
Grau, 2007^161^ Calcium Polyp Prevention Study^A^ US (34°-44°N) [17227996] | - Health status; - Mean age(range/SD), y; - Male (%) | Generally healthy men and women with a recent colorectal adenoma 60.6 71.7 | Calcium, mean: 876 mg/d^B^ | Elemental calcium,1200 mg/d | nd | Duplicated with Wallace; results during the observational post-intervention phase (5–10 years)
Nonrandomized comparative study
Duris, 1996^162^ nd Slovakia (48°N) [8682453] | - Health status; - Mean age(range/SD), y; - Male (%) | Generally healthy men and women; history of adenomatous polyps after polypectomy 54.7 62 | nd | Calcium carbonicum (2 g/d) | | No statistical comparison between groups

A A post-hoc followup study (Calcium Follow-up Study) of a RCT (Calcium Polyp Prevention Study).

B Two percent of the participants in the both groups took calcium supplements during the intervention period. Forty-seven percent in the placebo group and 49 percent in the supplement arm took any calcium supplements during the followup period after the intervention. The dosage was not reported (based on the self-reported data in the earlier report).160

Table 65 Calcium and colorectal adenoma: Characteristics of cohort studies

Author, Year Trial/Cohort Name Country (Latitude) [Pubmed ID] | Population | | Dietary Calcium intake | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author, Year Trial/Cohort Name Country (Latitude) [Pubmed ID] | Population | | Dietary Calcium intake | | Comparisons | Nutrients | Demographic | Anthrop | Medical | Seasons | Life styles | Comments
Cohort
Oh, 2007^163^ The Nurses Health Study US (38°N) [17379616] | - Health status; - Mean age(range/SD), y; - Male (%) | Generally healthy women 30–55 0 | Dietary assessment methodInternal validation? (y/n) | 61-item semi- quantitative FFQ(by Willet) y | Colorectal adenoma across total calcium intake quintiles | x | x | x | x | | x | Total Ca (both)
Kesse, 2005^141^ Etude Epidémiologique auprès de femmes de l’Education Nationale France (46°N) [15880532] | - Health status; - Mean age(range/SD), y; - Male (%) | Generally healthy women 52.7 0 | Dietary assessment methodInternal validation? (y/n) | FFQ y | Colorectal adenomas across total calcium intake quartiles | x | x | x | | | x | Total Ca (both)
Hartman, 2005^164^ The Polyp Prevention Trial US (38° N) [15671222] | - Health status; - Mean age(range/SD), y; - Male (%) | Generally healthy men and women; history of at least one colorectal adenoma; 90% Caucasian 61.1 (9.9) 64 | Dietary assessmentInternal method validation? (y/n) | FFQ y | Adenoma recurrence across total calcium intake quintiles | x | x | x | x | | | Total Ca (both)
Martinez, 2002^165^ Wheat Bran Fiber (WBF) trial US (33° N) [12020102] | - Health status; - Mean age(range/SD), y; - Male (%) | Generally healthy men and women; history of colorectal adenoma(s) nd 57.1 | Dietary assessment methodInternal validation? (y/n) | 113-item Arizona Food Frequency Questionnaire (AFFQ) y | Adenoma recurrence across total calcium intake quartiles Subgroup analyses per gender | x | x | | x | | | Total Ca (food)

Table 66 Calcium and colorectal adenoma recurrence: Results of RCTs

Author Year Name Location (Latitude) [PMID] | Life Stage | Outcome | 1°/2° | Mean Followup, mo | Interventions, Daily Dose | n Event | N Total | Outcome Metric (Comparison) | Result | 95% CI | P Btw | Study Quality
Grau 2007^161^ Calcium Polyp Prevention Study US (various) [17227996] | Adult | All adenomas | 1° | 92.4 | Calcium carbonate (1200 mg/d) | 82 | 208 | RR | 1.09 | 0.85, 1.39 | 0.51 | B
Grau 2007^161^ Calcium Polyp Prevention Study US (various) [17227996] | Adult | All adenomas | 1° | 92.4 | Placebo | 82 | 216 | | | | | B

Table 67 Calcium and colorectal adenoma recurrence: Results of nonrandomized comparative study

Author Year Study Name [PMID] | Life Stage | Outcome | 1°/2° | Mean Followup, mo | Interventions, Daily Dose | n Event | N Total | Outcome Metric (Comparison) | Result | 95% CI | P Btw | Study Quality
Duris 1996^162^ Slovakia (48°N) [8682453] | Adult (30–75 y) | Adenoma recurrence | nd | 37.2 | Calcium carbonicum, 2g/d No chemoprevention | 12 5 | 175 9 | RR | nd | nd | nd | C

Table 68 Calcium and colorectal adenoma: Results of cohort studies

Author Year Study Name Location (Latitude) [PMID] | Life Stage | Outcome (n/N, Incidence) | Total Ca Intake, mg/day | No. of Cases | No. in Category | Follow up Duration (Time to Dx) | Adjusted RR | 95% CI | P for Trend | Study Quality
Oh 2007^163^ The Nurses Health Study US (38°N) [17379616] | Female adult (30–55 y) | Adenoma (nd) | Median Q1, 584 | nd | nd | nd | 1.0 | Reference | 0.06 | B
Oh 2007^163^ The Nurses Health Study US (38°N) [17379616] | Female adult (30–55 y) | Adenoma (nd) | Median Q2, 779 | nd | nd | nd | 1.05 | 0.93, 1.20 | 0.06 | B
Oh 2007^163^ The Nurses Health Study US (38°N) [17379616] | Female adult (30–55 y) | Adenoma (nd) | Median Q3, 949 | nd | nd | nd | 0.96 | 0.84, 1.11 | 0.06 | B
Oh 2007^163^ The Nurses Health Study US (38°N) [17379616] | Female adult (30–55 y) | Adenoma (nd) | Median Q4, 1139 | nd | nd | nd | 0.96 | 0.82, 1.12 | 0.06 | B
Oh 2007^163^ The Nurses Health Study US (38°N) [17379616] | Female adult (30–55 y) | Adenoma (nd) | Median Q5, 1451 | nd | nd | nd | 0.88 | 0.74, 1.04 | 0.06 | B
Kesse 2005^141^ Etude Epidémiologique auprès de femmes de l’Education Nationale France (46°N) [15880532] | Female adult (40–65 y) | Adenoma (nd) | <785.62 | 154 | nd | 44.4 mo | 1.0 | Reference | 0.04 | B
Kesse 2005^141^ Etude Epidémiologique auprès de femmes de l’Education Nationale France (46°N) [15880532] | Female adult (40–65 y) | Adenoma (nd) | 785.62–1226.16 | 150 | nd | 44.4 mo | 0.97 | 0.76, 1.22 | 0.04 | B
Kesse 2005^141^ Etude Epidémiologique auprès de femmes de l’Education Nationale France (46°N) [15880532] | Female adult (40–65 y) | Adenoma (nd) | 981.67–1226.16 | 131 | nd | 44.4 mo | 0.83 | 0.65, 1.07 | 0.04 | B
Kesse 2005^141^ Etude Epidémiologique auprès de femmes de l’Education Nationale France (46°N) [15880532] | Female adult (40–65 y) | Adenoma (nd) | >1226.16 | 156 | nd | 44.4 mo | 0.80 | 0.62, 1.03 | 0.04 | B
Hartman 2005^164^ The Polyp Prevention Trial US (38° N) [15671222] | Adult (≥ 35 y) | Adenoma recurrence (nd) | < 666 | 156 | nd | nd | 1.0 | Reference | 0.20 | B
Hartman 2005^164^ The Polyp Prevention Trial US (38° N) [15671222] | Adult (≥ 35 y) | Adenoma recurrence (nd) | 666–814 | 163 | nd | nd | 1.12 | 0.83, 1.51 | 0.20 | B
Hartman 2005^164^ The Polyp Prevention Trial US (38° N) [15671222] | Adult (≥ 35 y) | Adenoma recurrence (nd) | 815–969 | 154 | nd | nd | 1.02 | 0.76, 1.38 | 0.20 | B
Hartman 2005^164^ The Polyp Prevention Trial US (38° N) [15671222] | Adult (≥ 35 y) | Adenoma recurrence (nd) | 970–1226 | 150 | nd | nd | 1.00 | 0.74, 1.36 | 0.20 | B
Hartman 2005^164^ The Polyp Prevention Trial US (38° N) [15671222] | Adult (≥ 35 y) | Adenoma recurrence (nd) | >1226 | 131 | nd | nd | 0.86 | 0.62, 1.18 | 0.20 | B
Martinez 2002^165^ Wheat Bran Fiber (WBF) trial US (38° N) [12020102] | Adult (40–80 y) | Adenoma recurrence (178/326; 0.55) | < 778 | 178 | 326 | 36.8 mo | 1.0 | Reference | 0.005 | B
Martinez 2002^165^ Wheat Bran Fiber (WBF) trial US (38° N) [12020102] | Adult (40–80 y) | Adenoma recurrence (175/326; 0.54) | 778–996 | 175 | 326 | 36.8 mo | 0.94 | 0.66, 1.32 | 0.005 | B
Martinez 2002^165^ Wheat Bran Fiber (WBF) trial US (38° N) [12020102] | Adult (40–80 y) | Adenoma recurrence (148/326; 0.45) | 997–1279 | 148 | 326 | 36.8 mo | 0.68 | 0.48, 0.97^*^ | 0.005 | B
Martinez 2002^165^ Wheat Bran Fiber (WBF) trial US (38° N) [12020102] | Adult (40–80 y) | Adenoma recurrence (138/326; 0.42) | >1279 | 138 | 326 | 36.8 mo | 0.62 | 0.42, 0.90^*^ | 0.005 | B
Martinez 2002^165^ Wheat Bran Fiber (WBF) trial US (38° N) [12020102] | Male adult (40–80 y) | Adenoma recurrence (nd) | < 778 | nd | nd | 36.8 mo | 1.0 | Reference | nd | B
Martinez 2002^165^ Wheat Bran Fiber (WBF) trial US (38° N) [12020102] | Male adult (40–80 y) | Adenoma recurrence (nd) | 778–996 | nd | nd | 36.8 mo | 1.01 | 0.68, 1.51 | nd | B
Martinez 2002^165^ Wheat Bran Fiber (WBF) trial US (38° N) [12020102] | Male adult (40–80 y) | Adenoma recurrence (nd) | 997–1279 | nd | nd | 36.8 mo | 0.83 | 0.54, 1.26 | nd | B
Martinez 2002^165^ Wheat Bran Fiber (WBF) trial US (38° N) [12020102] | Male adult (40–80 y) | Adenoma recurrence (nd) | >1279 | nd | nd | 36.8 mo | 0.67 | 0.40, 1.10 | nd | B
Martinez 2002^165^ Wheat Bran Fiber (WBF) trial US (38° N) [12020102] | Female adult (40–80 y) | Adenoma recurrence (nd) | < 778 | nd | nd | 36.8 mo | 1.0 | Reference | nd | B
Martinez 2002^165^ Wheat Bran Fiber (WBF) trial US (38° N) [12020102] | Female adult (40–80 y) | Adenoma recurrence (nd) | 778–996 | nd | nd | 36.8 mo | 0.81 | 0.40, 1.64 | nd | B
Martinez 2002^165^ Wheat Bran Fiber (WBF) trial US (38° N) [12020102] | Female adult (40–80 y) | Adenoma recurrence (nd) | 997–1279 | nd | nd | 36.8 mo | 0.42 | 0.21, 1.87 | nd | B
Martinez 2002^165^ Wheat Bran Fiber (WBF) trial US (38° N) [12020102] | Female adult (40–80 y) | Adenoma recurrence (nd) | >1279 | nd | nd | 36.8 mo | 0.52 | 0.28, 0.98^*^ | nd | B

Figure 19 Colorectal adenomatous polyp risk stratified by calcium intake

One systematic review included two RCTs that recruited high risk population for colorectal adenoma due to previous adenomatous polyps.139 A total of 1346 participants were analyzed for the effect of calcium supplementation (1200 to 2000 mg elemental calcium daily). The odds ratio of colorectal adenoma recurrence was 0.74 (95 percent CI 0.58, 0.95; P=0.02), comparing calcium supplementation to the placebo. A B quality post hoc followup analysis161 of one of the two RCTs that were included in the meta-analysis examined the long-term effect of calcium supplementation to prevent colorectal adenoma recurrence. The trial recruited participants with previous colorectal adenoma, and compared the preventative efficacy of calcium supplementation (1200 mg/d) to placebo. Adenoma recurrence at 4 years was the original primary outcome. During the followup period after the trial treatment, about 50 percent of participants in both groups took some calcium supplements. In 347 participants who underwent colonoscopy during the first 5 years after the intervention period, the relative risk of adenoma recurrence was 0.63 (95 percent CI 0.46, 0.87; P=0.005) comparing calcium supplementation to placebo, whereas no difference was found in 424 participants who underwent colonoscopy in the subsequent 5 to 10 years after the trial treatment.

A nonrandomized comparative study162 presented the percentage of adenoma recurrence in a group of men and women who underwent polypectomy, and received calcium supplementation (2000 mg/d) as chemoprevention. The same study also presented the percentage of adenoma recurrence in a group of men and women who underwent polypectomy but were not supplemented with calcium. The intervention group included 175 participants while the nonsupplemented group included nine patients. The two groups were followed for an average of 3.1 years. The trial was rated C for methodological quality. In this study,162 the percentage of participants with adenoma recurrence was lower in the intervention group compared to the nonsupplemented participants (13 percent versus 55 percent); however, no further statistical analysis was provided.

Four cohort studies evaluated the association between calcium intake and colorectal adenoma.141,163–165 Three studies were conducted in the US (latitude range between 33°N and 38°N), and one in France (latitude 46°N). Sample sizes ranged from 1304 to 48,115. Two studies recruited participants with a history of colorectal adenoma, and the other two recruited healthy subjects without a history of adenoma. The incidence rate of colorectal adenomas ranged between 0.003 and 0.025. The participants’ mean age ranged from 52.7 to 61.1 years. Average followup ranged from 36.8 to 44.4 months. Three of the four studies did not report information on assessor blinding.141,164,165 All studies assessed dietary intake with food frequency questionnaires and confirmed cases with pathology reports. The quality of all four studies was rated B.

Findings by age and sex

One cohort study165 that analyzed men and women (aged 40–80 y) with a history of colorectal adenoma found an inverse association between total calcium intake and colorectal adenoma recurrence after an average of 3.1 years of followup (RR 0.62, highest [>1279 mg/d] compared with lowest intake [<778 mg/d]; P for trend = 0.005). The study did not test statistically whether the strength of the association differed between men and women. Another study of both men and women with previous adenomatous polyps found no significant association between total calcium intake and colorectal adenoma recurrence.

One cohort study that analyzed exclusively women (aged 40–65 y) without a history of colorectal adenoma found an inverse association between total calcium intake and colorectal adenoma (RR 0.80, highest [>1226 mg/d] compared with lowest intake [<786 mg/d]; P for trend = 0.04).141 Another study of women without previous adenomatous polyps found no significant association.163

Findings by life stage

- 0–6 mo No data
- 7 mo–2 y No data
- 3–8 y No data
- 9–18 y No data
- 19–50 y One cohort study of women age 30 to 55 years found no association between total calcium intakes and colorectal adenoma. Three additional studies included some men or women in this life stage. Two of these studies reported a significant inverse association between total calcium intake and colorectal adenoma. However, their results are inconclusive for adults in this life stage.
- 51–70 y One meta-analysis of 2 RCTs in adults with previous adenomatous polyps (mean age 59 to 61 years) found a significant decrease in colorectal adenoma recurrence in supplemental calcium (1200 to 2000 mg elemental calcium daily) compared to no supplements (odds ratio, 0.74 [95 percent CI 0.58, 0.95]; P=0.02). A long-term followup study of one of the two trials found no difference in recurrence after 5 to 10 years after the intervention. One nonrandomized comparative trial also found a significant reduction in adenoma recurrence risk among healthy adults with a mean age 55 years who received calcium supplementation compared to no supplements (13 percent vs. 55 percent; P value not reported). Two cohort studies evaluated participants with a mean age 53 and 61 years respectively. One additional study recruited adults in this life stage. Two of the three studies, one including adults with a history of adenoma and another including women without adenoma history, found an inverse association between total calcium intake and colorectal adenoma.
- 71+ No studies specifically focused on this life stage. Two studies also included some men and women with a history of adenoma corresponding to this life stage. One found an inverse association between total calcium intake and colorectal adenoma, while the other did not find such an association.
- Postmenopause No data
- Pregnant & lactating women No data

#### Breast cancer incidence

Synopsis

No qualified systematic reviews evaluated the association between dietary and supplemental calcium intake and the risk of breast cancer. No RCTs were identified. Six cohort studies compared calcium intake and the risk of breast cancer. In four studies, premenopausal women with calcium intakes in the range of 780–1750 mg/d had a decreased risk of incident breast cancer.125, 166–170 Only one study reported decreased risk of breast cancer in both premenopausal and postmenopausal women for calcium intake ranged from 1250 to 1750 mg/d compared with the lowest quintile of intake of less than 500 mg/d.168 In two of six studies, there was no association between calcium intake and breast cancer (both overall and by menopausal status).125, 170 Five studies were rated B and one study rated C.

Detailed presentation

(Tables 69 & 70; Figure 20)

Table 69 Calcium and breast cancer: Characteristics of cohort studies

Author Year Study Name Location (Latitude) [PMID] | Population | | Dietary Calcium intake | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Study Name Location (Latitude) [PMID] | Population | | Dietary Calcium intake | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV exposure | Lifestyle | Comments
Cohort
Park 2009 NIH-AARP US 38° N [19237724] | - Health status; - Mean age(range/SD), y | No cancer 50–71 | - Dietary assessment method; - Internal validation? (y/n) | FFQ (NCI-DHQ) USDA Nutrient Database y | Quintile 1 vs. Quintile 2, 3, 4, 5 | x | x | x | x | | x | Total calcium intake from diet and supplement
Shin 2002^169^ NHS US 38° N [12208895] | - Health status; - Mean age(range/SD), y | No cancer 47 (ND) | - Dietary assessment method; - Internal validation? (y/n) | 61 item FFQ USDA Nutrient Database y | 500 mg vs. 500–600, 600–700, 700–800, 800–1000, 1000–1250, >1250 | x | x | x | x | x | x | Total calcium intake from diet and supplement
McCullough 2005^168^ CPS II Nutrition Cohort US 38° N [16365007] | - Health status; - Mean age (range/SD), y | No cancer 63 (ND) | - Dietary assessment method; - Internal validation? (y/n) | Modified FFQ of Block et al. y | 500 mg vs. 500–750, 750–1000, 1000–1250, 1250–1500, 1500–1750, >1750 | x | x | x | x | x | x | Total calcium intake from diet and supplement
Larsson 2009^170^ Swedish Mammography Cohort Sweden 62° N [19056569] | - Health status; - Mean age (range/SD), y | No cancer 53.7 (9.7) | - Dietary assessment method; - Internal validation? (y/n) | FFQ Swedish National Food Administration Database y | <727 vs. 727–862, 863–980, 980–1125, >1125 | x | x | x | | x | x | Total calcium intake from diet and supplement
Lin J 2007^167^ WHS US 38° N [17533208] | - Health status; - Mean age (range/SD), y | No cancer or CVD 55(55–56) | - Dietary assessment method; - Internal validation? (y/n) | Willet method USDA Nutrient Database y | Quintile 1 vs. Quintile 2, 3, 4, 5 | x | x | x | | x | x | Total calcium intake from diet and supplement
Kesse-Guyot 2007^166^ SU.VI.MAX France 46° N [17536191] | - Health status; - Mean age (range/SD), y | No cancer 51(6.3) | - Dietary assessment method; - Internal validation? (y/n) | Computerized questionnaires ND | Quintile 1 vs. Quintile 2, 3, 4 | x | x | x | | x | x | Dietary calcium intake

Table 70 Calcium and breast cancer: Results of cohort studies

Author Year Study Name [PMID] | Life Stage | Outcome (n/N; Incidence) | Follow up Duration (Time to Dx) | Total Ca Intake, mg/day | No. of Cases | No. in Category | Adjusted RR | 95% CI | P for Trend | Study Quality
Park 2009^125^ NIH-AARP [19237724] | Pre- and Post-menopausal women | Breast cancer (5856/198,903; 2.9%) | 7 y | Q1 | 494 | 5856 | HR 1 | Reference | NS | B
Park 2009^125^ NIH-AARP [19237724] | Pre- and Post-menopausal women | Breast cancer (5856/198,903; 2.9%) | 7 y | Q2 | 717 | 5856 | 0.96 | 0.88–1.04 | NS | B
Park 2009^125^ NIH-AARP [19237724] | Pre- and Post-menopausal women | Breast cancer (5856/198,903; 2.9%) | 7 y | Q3 | 969 | 5856 | 0.95 | 0.87–1.03 | NS | B
Park 2009^125^ NIH-AARP [19237724] | Pre- and Post-menopausal women | Breast cancer (5856/198,903; 2.9%) | 7 y | Q4 | 1296 | 5856 | 0.94 | 0.86–1.02 | NS | B
Park 2009^125^ NIH-AARP [19237724] | Pre- and Post-menopausal women | Breast cancer (5856/198,903; 2.9%) | 7 y | Q5 | 1881 | 5856 | 0.98 | 0.90–1.07 | NS | B
Shin 2002^169^ NHS [12208895] | Pre-menopausal women | Breast cancer (3172/88,381; 3.6%) | 16 y | ≤500 | 142 | ND | 1 | Reference | 0.05 | B
Shin 2002^169^ NHS [12208895] | Pre-menopausal women | Breast cancer (3172/88,381; 3.6%) | 16 y | 500–600 | 106 | ND | 0.88 | 0.68, 1.13 | 0.05 | B
Shin 2002^169^ NHS [12208895] | Pre-menopausal women | Breast cancer (3172/88,381; 3.6%) | 16 y | 600–700 | 133 | ND | 0.97 | 0.76, 1.24 | 0.05 | B
Shin 2002^169^ NHS [12208895] | Pre-menopausal women | Breast cancer (3172/88,381; 3.6%) | 16 y | 700–800 | 119 | ND | 0.95 | 0.74, 1.22 | 0.05 | B
Shin 2002^169^ NHS [12208895] | Pre-menopausal women | Breast cancer (3172/88,381; 3.6%) | 16 y | 800–1000 | 161 | ND | 0.82 | 0.64, 1.05 | 0.05 | B
Shin 2002^169^ NHS [12208895] | Pre-menopausal women | Breast cancer (3172/88,381; 3.6%) | 16 y | 1000–1250 | 104 | ND | 0.75 | 0.57, 0.99^*^ | 0.05 | B
Shin 2002^169^ NHS [12208895] | Pre-menopausal women | Breast cancer (3172/88,381; 3.6%) | 16 y | >1250 | 62 | ND | 0.80 | 0.58, 1.12 | 0.05 | B
Shin 2002^169^ NHS [12208895] | Post-menopausal women | | | ≤500 | 240 | ND | 1 | Reference | NS | B
Shin 2002^169^ NHS [12208895] | Post-menopausal women | | | 500–600 | 216 | ND | 0.86 | 0.72, 1.04 | NS | B
Shin 2002^169^ NHS [12208895] | Post-menopausal women | | | 600–700 | 293 | ND | 0.94 | 0.79, 1.12 | NS | B
Shin 2002^169^ NHS [12208895] | Post-menopausal women | | | 700–800 | 292 | ND | 0.92 | 0.77, 1.10 | NS | B
Shin 2002^169^ NHS [12208895] | Post-menopausal women | | | 800–1000 | 518 | ND | 0.93 | 0.79, 1.10 | NS | B
Shin 2002^169^ NHS [12208895] | Post-menopausal women | | | 1000–1250 | 433 | ND | 0.90 | 0.76, 1.07 | NS | B
Shin 2002^169^ NHS [12208895] | Post-menopausal women | | | >1250 | 353 | ND | 0.93 | 0.77, 1.12 | NS | B
McCullough2005^168^ CPS II Nutrition Cohort [16365007] | Pre- and Post-menopausal women | Breast cancer (2855/68,567; 4.1%) | 8 y | 500 | 457 | 10,620 | 1 | Reference | 0.07 | B
McCullough2005^168^ CPS II Nutrition Cohort [16365007] | Pre- and Post-menopausal women | Breast cancer (2855/68,567; 4.1%) | 8 y | 500–750 | 729 | 17,880 | 0.91 | 0.81, 1.02 | 0.07 | B
McCullough2005^168^ CPS II Nutrition Cohort [16365007] | Pre- and Post-menopausal women | Breast cancer (2855/68,567; 4.1%) | 8 y | 750–1000 | 581 | 14,023 | 0.92 | 0.81, 1.04 | 0.07 | B
McCullough2005^168^ CPS II Nutrition Cohort [16365007] | Pre- and Post-menopausal women | Breast cancer (2855/68,567; 4.1%) | 8 y | 1000–1250 | 407 | 9120 | 0.97 | 0.85, 1.11 | 0.07 | B
McCullough2005^168^ CPS II Nutrition Cohort [16365007] | Pre- and Post-menopausal women | Breast cancer (2855/68,567; 4.1%) | 8 y | 1250–1500 | 248 | 6296 | 0.84 | 0.72, 0.98^*^ | 0.07 | B
McCullough2005^168^ CPS II Nutrition Cohort [16365007] | Pre- and Post-menopausal women | Breast cancer (2855/68,567; 4.1%) | 8 y | 1500–1750 | 144 | 3983 | 0.76 | 0.63, 0.92^*^ | 0.07 | B
McCullough2005^168^ CPS II Nutrition Cohort [16365007] | Pre- and Post-menopausal women | Breast cancer (2855/68,567; 4.1%) | 8 y | 1750 | 289 | 6645 | 0.91 | 0.79, 1.06 | 0.07 | B
Larsson 2009^170^ Swedish Mammography Cohort [19056569] | Pre- and Post-menopausal women | Invasive Breast cancer (2952/61,433; 4.8%) | 9 y | <727 | 595 | 2952 | 1 | Reference | NS | B
Larsson 2009^170^ Swedish Mammography Cohort [19056569] | Pre- and Post-menopausal women | Invasive Breast cancer (2952/61,433; 4.8%) | 9 y | 727–862 | 595 | 2952 | 0.97 | 0.87–1.09 | NS | B
Larsson 2009^170^ Swedish Mammography Cohort [19056569] | Pre- and Post-menopausal women | Invasive Breast cancer (2952/61,433; 4.8%) | 9 y | 863–980 | 592 | 2952 | 0.95 | 0.84–1.06 | NS | B
Larsson 2009^170^ Swedish Mammography Cohort [19056569] | Pre- and Post-menopausal women | Invasive Breast cancer (2952/61,433; 4.8%) | 9 y | 980–1125 | 571 | 2952 | 0.93 | 0.83–1.04 | NS | B
Larsson 2009^170^ Swedish Mammography Cohort [19056569] | Pre- and Post-menopausal women | Invasive Breast cancer (2952/61,433; 4.8%) | 9 y | >1125 | 599 | 2952 | 0.97 | 0.87–1.09 | NS | B
Lin J 2007^167^ WHS [17533208] | Pre-menopausal women | Invasive breast cancer (878/31,487; 2.8%) | 10 y | <617 | 70 | 10,578 | HR 1 | Reference | .04 | B
Lin J 2007^167^ WHS [17533208] | Pre-menopausal women | Invasive breast cancer (878/31,487; 2.8%) | 10 y | 617–789 | 65 | 10,578 | 0.84 | 0.59, 1.19 | .04 | B
Lin J 2007^167^ WHS [17533208] | Pre-menopausal women | Invasive breast cancer (878/31,487; 2.8%) | 10 y | 789–1026 | 44 | 10,578 | 0.60 | 0.41, 0.88^*^ | .04 | B
Lin J 2007^167^ WHS [17533208] | Pre-menopausal women | Invasive breast cancer (878/31,487; 2.8%) | 10 y | 1026–1366 | 59 | 10,578 | 0.79 | 0.55, 1.14 | .04 | B
Lin J 2007^167^ WHS [17533208] | Pre-menopausal women | Invasive breast cancer (878/31,487; 2.8%) | 10 y | ≥1366 | 38 | 10,578 | 0.61 | 0.40, 0.92^*^ | .04 | B
Lin J 2007^167^ WHS [17533208] | Post-menopausal women | | | <617 | 104 | 20,909 | HR 1 | Reference | NS | B
Lin J 2007^167^ WHS [17533208] | Post-menopausal women | | | 617–789 | 116 | 20,909 | 1.21 | 0.95, 1.54 | NS | B
Lin J 2007^167^ WHS [17533208] | Post-menopausal women | | | 789–1026 | 112 | 20,909 | 1.09 | 0.85, 1.40 | NS | B
Lin J 2007^167^ WHS [17533208] | Post-menopausal women | | | 1026–1366 | 119 | 20,909 | 1.21 | 0.95, 1.55 | NS | B
Lin J 2007^167^ WHS [17533208] | Post-menopausal women | | | ≥1366 | 151 | 20,909 | 1.17 | 0.92, 1.50 | NS | B
Kesse-Guyot 2007^166^ SU.VI.MAX trial [17536191] | Pre- and Post- menopausal | Breast cancer (92/3627; 2.5%) | 8 y | <807 | 32 | 3627 | 1 | Reference | 0.04 | C
Kesse-Guyot 2007^166^ SU.VI.MAX trial [17536191] | Pre- and Post- menopausal | Breast cancer (92/3627; 2.5%) | 8 y | 807–960 | 24 | 3627 | 0.73 | 0.42, 1.25 | 0.04 | C
Kesse-Guyot 2007^166^ SU.VI.MAX trial [17536191] | Pre- and Post- menopausal | Breast cancer (92/3627; 2.5%) | 8 y | 961–1144 | 20 | 3627 | 0.65 | 0.37, 1.14 | 0.04 | C
Kesse-Guyot 2007^166^ SU.VI.MAX trial [17536191] | Pre- and Post- menopausal | Breast cancer (92/3627; 2.5%) | 8 y | >1144 | 16 | 3627 | 0.50 | 0.27, 0.91^*^ | 0.04 | C
Kesse-Guyot 2007^166^ SU.VI.MAX trial [17536191] | Post-menopausal | | | <807 | 14 | nd | 1 | Reference | 0.64 | C
Kesse-Guyot 2007^166^ SU.VI.MAX trial [17536191] | Post-menopausal | | | 807–960 | 13 | nd | 0.71 | 0.33, 1.54 | 0.64 | C
Kesse-Guyot 2007^166^ SU.VI.MAX trial [17536191] | Post-menopausal | | | 961–1144 | 10 | nd | 0.67 | 0.30, 1.53 | 0.64 | C
Kesse-Guyot 2007^166^ SU.VI.MAX trial [17536191] | Post-menopausal | | | >1144 | 11 | nd | 0.76 | 0.34, 1.70 | 0.64 | C
Kesse-Guyot 2007^166^ SU.VI.MAX trial [17536191] | Pre-menopausal | | | <807 | 18 | nd | 1 | Reference | 0.01 | C
Kesse-Guyot 2007^166^ SU.VI.MAX trial [17536191] | Pre-menopausal | | | 807–960 | 11 | nd | 0.77 | 0.36, 1.66 | 0.01 | C
Kesse-Guyot 2007^166^ SU.VI.MAX trial [17536191] | Pre-menopausal | | | 961–1144 | 10 | nd | 0.63 | 0.29, 1.38 | 0.01 | C
Kesse-Guyot 2007^166^ SU.VI.MAX trial [17536191] | Pre-menopausal | | | >1144 | 5 | Nd | 0.26 | 0.10, 0.71^*^ | 0.01 | C

HR: hazard ratio

* Statistically significant (P<0.05)

Figure 20 Breast cancer risk stratified by calcium intake

Six studies recruited a total of 452,398 (ranged from 3600 to 198,903) pre-and postmenopausal women and followed them for a period of 7 to 16 years. The participants had an average age ranged from 47 to 63 years. Four studies conducted in the US and one study conducted in Sweden used validated food frequency questionnaire to quantify calcium intake levels. One study conducted in France used computerized questionnaire to quantify calcium intake levels. The incidence of breast cancer in these studies ranged from 2.5 to 4.8 percent. In four of the six cohort studies, premenopausal women with calcium intakes in the range of 780 to 1750 mg/d had a decreased risk of incident breast cancer compared to those with lowest quintile intake levels in each study. There was no association between calcium intake and breast cancer in the two of six studies.125, 170

Findings by age and sex

In subgroup analysis of four cohort studies, premenopausal women had a consistently decreased risk of breast cancer. No association was found for postmenopausal women.

Findings by life stage

- 0–6 mo Not applicable
- 7 mo–2 y Not applicable
- 3–8 y Not applicable
- 9–18 y Not applicable
- 19–50 y A cohort study of Nurses’ Health Study including women with an average age of 47 years had a decrease risk (RR 0.75, 95 percent CI 0.55, 0.99) in breast cancer among those with calcium intake levels of 1000–1250 mg/d compared to those with intake levels lesser than 500 mg/d.
- 51–70 y Three of the five cohort studies of women with an average age between 51–63 years, found a decreased risk of breast cancer among those with calcium intakes in the range of 780–1750 mg/d compared to those with lowest quintile intake levels in each study.
- ≥71 y Not reviewed
- Postmenopause Cohort studies did not find an association between breast cancer risk and calcium intake levels among postmenopausal women.
- Pregnant & lactating women Not reviewed

#### Breast Mammographic Density

Synopsis

No systematic reviews evaluated the association between dietary and supplemental calcium intake and breast mammographic density. No RCTs of calcium intake evaluated breast mammography density. One prospective cohort study evaluated the association of calcium intake and breast mammographic density.171 Both premenopausal and postmenopausal women with calcium intakes in the range of 523 mg/d to greater than 1021 mg/d were followed for almost 40 years, and there was no association between calcium intake and breast mammographic density. The methodological quality of this study was rated B.

Detailed presentation

(Tables 71 & 72)

Table 71 Calcium and breast mammography density: Characteristics of cohort studies

Author Year Study Name Location (Latitude) [PMID] | Population | | Dietary Calcium intake | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Study Name Location (Latitude) [PMID] | Population | | Dietary Calcium intake | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV exposure | Lifestyle | Comments
Cohort
Mishra 2008^171^ Medical MRC NSHD UK 54° N [18827811] | - •Health status; - Mean age(range/SD), y | No breast cancer 52 | Dietary assessment methodInternal validation? (y/n) | 5-day food diaries McCance and Widdowson’s food table ND | At age 36 y: <523, 524-648652-784, 785-940, 941 At age 43 y: <611, 612–735, 736–859, 860–1020, >1021 | x | x | x | x | | x | Total calcium intake from diet and supplement

Table 72 Calcium and breast cancer: Results of cohort studies

Author Year Study Name [PMID] | Life Stage | Outcome (n/N; Incidence) | Follow up Duration (Time to Dx) | Total Ca Intake, mg/day | No. of Cases | No. in Category | Adjusted RR | 95% CI | P for Trend | Study Quality
Mishra 2008^171^ Medical MRC NSHD [18827811] | Premenopausal women | Breast cancer density (nd; median21.9%) | ~32 y | ≤523 | 133 | 766 | βcoefficient 1 | Reference | NS | B
Mishra 2008^171^ Medical MRC NSHD [18827811] | Premenopausal women | Breast cancer density (nd; median21.9%) | ~32 y | 524–648 | 143 | 766 | −0.11 | −0.33, 0.10 | NS | B
Mishra 2008^171^ Medical MRC NSHD [18827811] | Premenopausal women | Breast cancer density (nd; median21.9%) | ~32 y | 652–784 | 156 | 766 | −0.05 | −0.27, 0.17 | NS | B
Mishra 2008^171^ Medical MRC NSHD [18827811] | Premenopausal women | Breast cancer density (nd; median21.9%) | ~32 y | 785–940 | 160 | 766 | −0.04 | −0.27, 0.19 | NS | B
Mishra 2008^171^ Medical MRC NSHD [18827811] | Premenopausal women | Breast cancer density (nd; median21.9%) | ~32 y | ≥941 | 174 | 766 | −0.08 | −0.32, 0.17 | NS | B
Mishra 2008^171^ Medical MRC NSHD [18827811] | Premenopausal women | Breast cancer density (nd; median21.9%) | ~39 y | ≤611 | 145 | 755 | βcoefficient 1 | Reference | NS | B
Mishra 2008^171^ Medical MRC NSHD [18827811] | Premenopausal women | Breast cancer density (nd; median21.9%) | ~39 y | 612–735 | 156 | 755 | −0.13 | −0.35, 0.09 | NS | B
Mishra 2008^171^ Medical MRC NSHD [18827811] | Premenopausal women | Breast cancer density (nd; median21.9%) | ~39 y | 736–859 | 145 | 755 | −0.06 | −0.29, 0.17 | NS | B
Mishra 2008^171^ Medical MRC NSHD [18827811] | Premenopausal women | Breast cancer density (nd; median21.9%) | ~39 y | 860–1020 | 156 | 755 | −0.11 | −0.34, 0.12 | NS | B
Mishra 2008^171^ Medical MRC NSHD [18827811] | Premenopausal women | Breast cancer density (nd; median21.9%) | ~39 y | ≥1021 | 153 | 755 | −0.16 | −0.42, 0.09 | NS | B

One prospective cohort study followed from birth of a British national representative sample of 2547 women and followed them for a period of 53 years.171 Women had an average age of 51.5 years. Dietary calcium intake was evaluated using 5-day food records. The breast density in women was assessed through mammography at the ages 36, 43, and 53 years. Since the measurement at the age of 53 years was cross-sectional, this has been excluded from our analyses. There was no linear association between dietary calcium intakes in the range of 523 mg/d to greater than 1021 mg/d and breast mammographic density.

Findings by age and sex

In subgroup analysis by age categories, there was no linear association between calcium intake and breast mammography density.

Findings by life stage

- 0–6 mo Not applicable
- 7 mo–2 y Not applicable
- 3–8 y Not applicable
- 9–18 y Not applicable
- 19–50 y There was no linear association between calcium intake in the range of 523 mg/d to greater than 1021 mg/d and breast mammographic density
- 51–70 y No data
- ≥71 y No data
- Postmenopause No data
- Pregnant & lactating women Not reviewed

#### Pancreatic cancer

We reviewed primary studies that evaluated associations between calcium intake and incidence of pancreatic cancer.

Synopsis

Two studies analyzed three US cohorts and found that total daily calcium intake was not associated with the risk of pancreatic cancer in men and women. No RCTs of calcium intake or supplement have evaluated this outcome.

Detailed presentation

(Tables 73 & 74)

Table 73 Calcium and pancreatic cancer: Characteristics of cohort studies

Author, Year Study Name Location (Latitude [PMID] | Population | | Dietary calcium intake | | Comparison s | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author, Year Study Name Location (Latitude [PMID] | Population | | Dietary calcium intake | | Comparison s | Nutrients | Demographic | Anthrop | Medical | UV exposure | Life styles | Comments
Skinner2006^172^ NHS, HPFS US (multiple latitudes) [16985031] | Health status Mean age(range/SD), y Male (%) | DM: NHS 3%; HPFS 1% NHS 51; HPFS 55 NHS 0; HPFS 100 | Dietary assessment methodInternal validation? (y/n) | 131-item FFQ (Willet, 1990) y | Pancreatic cancer risk stratified by different intakes of calcium (dietary and supplement combined) | X | X | X | X | X | X | Current >smoker ~23%
Park 2009^125^ NIH-AARP US 38°N [19237724] | - Health status; - Mean age(range/), y; - Male (%) | No cancer 50–71 60 | Dietary assessment methodInternal validation? (y/n) | FFQ (NCI-DHQ) USDA Nutrient Database y | Pancreatic cancer risk stratified by quintile of total calcium intake | X | X | X | X | | X | Total calcium intake from diet and supplement

Table 74 Calcium and pancreatic cancer: Results of cohort studies

Author Year Study Name [PMID] | Life Stage, y | Outcome (n/N; Incidence) | Followup Duration, y | Total Ca intake in mg/d | No. of Cases | Total no. in Category | Adjusted RR | 95% CI | P for Trend | Study Quality
Skinner 2006^172^ NHS, HPFS US (multiple latitudes) [16985031] | 19–50 51–70 ≥71 | Pancreatic cancer (365/122,198; 0.003) overall | 14.5 | <500 | 41 | nd | 1 | Reference | 0.29 | A
Skinner 2006^172^ NHS, HPFS US (multiple latitudes) [16985031] | 19–50 51–70 ≥71 | Pancreatic cancer (365/122,198; 0.003) overall | 14.5 | 500–999 | 228 | nd | 1.17 | 0.83, 1.66 | 0.29 | A
Skinner 2006^172^ NHS, HPFS US (multiple latitudes) [16985031] | 19–50 51–70 ≥71 | Pancreatic cancer (365/122,198; 0.003) overall | 14.5 | ≥1000 | 96 | nd | 0.94 | 0.62, 1.41 | 0.29 | A
Skinner 2006^172^ NHS, HPFS US (multiple latitudes) [16985031] | 19–50 51–70 women | Pancreatic cancer (178/75,427; 0.002) NHS | 15.4 | <500 | 24 | nd | 1 | Reference | 0.09 | A
Skinner 2006^172^ NHS, HPFS US (multiple latitudes) [16985031] | 19–50 51–70 women | Pancreatic cancer (178/75,427; 0.002) NHS | 15.4 | 500–999 | 109 | nd | 1.09 | 0.69, 1.73 | 0.09 | A
Skinner 2006^172^ NHS, HPFS US (multiple latitudes) [16985031] | 19–50 51–70 women | Pancreatic cancer (178/75,427; 0.002) NHS | 15.4 | ≥1000 | 45 | nd | 0.75 | 0.43, 1.30 | 0.09 | A
Skinner 2006^172^ NHS, HPFS US (multiple latitudes) [16985031] | 19–50 51–70 ≥71 men | Pancreatic cancer (187/46,771; 0.004) HPFS | 13.1 | <500 | 17 | nd | 1 | Reference | 0.86 | A
Skinner 2006^172^ NHS, HPFS US (multiple latitudes) [16985031] | 19–50 51–70 ≥71 men | Pancreatic cancer (187/46,771; 0.004) HPFS | 13.1 | 500–999 | 119 | nd | 1.28 | 0.76, 2.18 | 0.86 | A
Skinner 2006^172^ NHS, HPFS US (multiple latitudes) [16985031] | 19–50 51–70 ≥71 men | Pancreatic cancer (187/46,771; 0.004) HPFS | 13.1 | ≥1000 | 51 | nd | 1.23 | 0.67, 2.25 | 0.86 | A
Park 2009 NIH-AARP125[19237724] | 50–71, men | Pancreatic cancer (717/293,907; 0.002) | 7 | 526 | 717 (total) | 293,907 (total) | 1 (HR) | Reference | 0.39 | B
Park 2009 NIH-AARP125[19237724] | 50–71, men | Pancreatic cancer (717/293,907; 0.002) | 7 | 498 | | | 0.93 | 0.74, 1.16 | 0.39 | B
Park 2009 NIH-AARP125[19237724] | 50–71, men | Pancreatic cancer (717/293,907; 0.002) | 7 | 857 | | | 0.9 | 0.72,1.14 | 0.39 | B
Park 2009 NIH-AARP125[19237724] | 50–71, men | Pancreatic cancer (717/293,907; 0.002) | 7 | 1073 | | | 0.98 | 0.78, 1.23 | 0.39 | B
Park 2009 NIH-AARP125[19237724] | 50–71, men | Pancreatic cancer (717/293,907; 0.002) | 7 | 1530 | | | 0.87 | 0.68, 1.11 | 0.39 | B
Park 2009 NIH-AARP125[19237724] | 50–71, women | Pancreatic cancer (384/198,903; 0.002) | 7 | 526 | 384 (total) | 198,903 (total) | 1 (HR) | Reference | 0.40
Park 2009 NIH-AARP125[19237724] | 50–71, women | Pancreatic cancer (384/198,903; 0.002) | 7 | 498 | | | 1.03 | 0.75, 1.40 | 0.40
Park 2009 NIH-AARP125[19237724] | 50–71, women | Pancreatic cancer (384/198,903; 0.002) | 7 | 857 | | | 0.93 | 0.67, 1.28 | 0.40
Park 2009 NIH-AARP125[19237724] | 50–71, women | Pancreatic cancer (384/198,903; 0.002) | 7 | 1073 | | | 0.97 | 0.71, 1.34 | 0.40
Park 2009 NIH-AARP125[19237724] | 50–71, women | Pancreatic cancer (384/198,903; 0.002) | 7 | 1530 | | | 0.88 | 0.63, 1.24 | 0.40

One study analyzed data from Nurses’ Health Study (NHS) and the Health Professionals Follow-up Study (HPFS).172 The study identified a total of 365 cases of pancreatic cancer (178/75,427 women aged 38 to 65 years from NHS; 178/46,771 men aged 40 to 75 years from HPFS). Comparing the group with at least 1000 mg/d of calcium intake to the group with less than 500 mg/d, there was no significant difference in the relative risk of pancreatic cancer (RR 0.94; 95 percent CI 0.62, 1.41 for overall; 0.75; 95 percent CI 0.43, 1.30 for NHS; 1.23; 95 percent CI 0.67, 2.25 for HPFS). The result was adjusted for age, categories of total vitamin D intake, smoking, diabetes, BMI, height, region of residence, use of multivitamin, and parity (for women). The pancreatic cancer was not stratified into endocrine versus exocrine tumors. Methodological quality of this study was rated A.

Another study analyzed data from AARP (the American Association of Retired Persons) members, aged 50 to 71 years old, living in six specific states in the US.125 The study identified a total of 717 and 384 cases of pancreatic cancer in men and women over 7 years of followup period, respectively. Pancreatic cancer was one of many other cancer outcomes evaluated in this study. The results showed that that total calcium intake was not associated with the risk of pancreatic cancer after controlling for potential risk factors pertinent to individual cancers. The methodological quality of this study was rated B.

Findings by life stage

- 0–6 mo Not reviewed
- 7 mo–2 y Not reviewed
- 3–8 y Not reviewed
- 9–18 y Not reviewed
- 19–50 y One study analyzed two US cohorts (NHS [women 38–65 y] and HPFS [men 40–75 y]) and found that total daily calcium intake was not associated with the risk of pancreatic cancer.
- 51–70 y One study analyzed two US cohorts (NHS [women 38–65 y] and HPFS [men 40–75 y]) and found that total daily calcium intake was not associated with the risk of pancreatic cancer. Another study analyzed US AARP cohort with men and women in this life stage found similar result.
- ≥71 y One study that analyzed HPFS included males up to 75 years old and found that total daily calcium intake was not associated with the risk of pancreatic cancer.
- Postmenopause No data
- Pregnant & lactating women Not reviewed

### Calcium and pregnancy-related outcomes

#### Preeclampsia

Synopsis

This summary is primarily based on a systematic review of 12 RCTs (n=15,528 women) of calcium supplementation (≥1000 mg/d) during pregnancy versus placebo for preventing preeclampsia. In addition, it includes findings from two cohort studies (one of which is a reanalysis of one of the 12 RCTs mentioned above).

Overall, the random effects meta-analysis of the 12 RCTs favored calcium supplementation (RR=0.48, 95 percent CI 0.33, 0.69), albeit with substantial between-study heterogeneity. More than 80 percent of the total number of randomized women (n=12,914) came from two large trials that found no significant effect of calcium supplementation for preventing preeclampsia (RR=0.95, 95 percent CI 0.89, 1.05). Based on their confidence interval, the two large studies excluded large effects of calcium for preeclampsia prevention. There is no obvious explanation for the observed between-study heterogeneity in the aforementioned meta-analysis. The heterogeneity stems from differences in the effects between smaller trials (claiming protective effects) and large trials (showing no effect).

The two cohort studies did not detect associations between calcium intake during the first or second trimester of pregnancy with preeclampsia. Both cohorts were rated B for methodological and reporting quality.

Based on the above, there is not a clear answer to whether calcium supplementation is effective for preeclampsia prevention.

Detailed presentation

(Tables 75, 76 & 77)

Table 75 Summary table of systematic review on calcium supplementation and preeclampsia, small for gestational age, preterm birth

Author Year [PMID] | Hofmeyr 2006^176^ [16855957]
Design (Search Years) | Randomized controlled trials (1988–2006)
Population | Pregnant women less than 35 weeks of gestation regardless of their risk of hypertensive of pregnancy or their previous calcium intake
Intervention (Exposure) and Comparator | Calcium supplement (at least 1000 mg/d) vs. placebo
Results | 12 trials (n=15,528)^A^ Preeclampsia (mother):; - All 12 trials (n=15,528): RR=0.48 (0.33, 0.69)^B^; statistically heterogeneous; - Among 4 trials (n=5022) with adequate Ca in diet: RR=0.62 (0.32, 1.20); statistically heterogeneous; - Among 7 trials (n=10,154) with low Ca in diet: RR=0.36 (0.18, 0.70); statistically heterogeneous; - Among 5 trials (n=587) at high risk for hypertension: RR=0.22 (0.12, 0.42); statistically homogeneous; - Among 6 trials (n=14,619) at low risk for hypertension: RR=0.68 (0.49, 0.94); statistically heterogeneous; High blood pressure with or without proteinuria (mother):; - Among 11 trials (n=14,946): RR= 0.70 (95% CI 0.57, 0.86); statistically heterogeneous; - Among 4 trials (n=5022) with adequate Ca in diet: RR=0.90 (0.81, 0.99); statistically homogeneous; - Among 6 trials (n=9684) with low Ca in diet: RR=0.47 (0.29, 0.76); statistically heterogeneous; - Among 4 trials (n=327) at high risk for hypertension: RR=0.47 (0.22, 0.97); statistically heterogeneous; - Among 7 trials (n=14,619) at low risk for hypertension: RR=0.78 (0.64, 0.95); statistically heterogeneous; Preterm birth:; - Among 10 trials (n=14,751): RR = 0.81 (0.64, 1.03); statistically heterogeneous; - Among 4 trials (n=5033) with adequate Ca in diet: RR=0.59 (0.26, 1.33); statistically heterogeneous; - Among 6 trials (n=9684) with low Ca in diet: RR=0.90 (0.80, 1.02); statistically homogeneous; - Among 4 trials (n=478) at high risk for hypertension: RR=0.45 (0.24, 0.83); statistically homogeneous; - Among 7 trials (n=14,183) at low risk for hypertension: RR=0.91 (0.74, 1.12); statistically heterogeneous; Small for gestational age (infant):; - Among 3 trials (n=13,091; fixed effects): RR = 1.10 (0.88, 1.37); statistically homogeneous
Comments | About 80% of participants are from two well designed and well conducted RCTs.178,179 The two large RCTs show no effects for all four outcomes
AMSTAR Criteria
A priori design? | Yes | Study quality assessment performed? | Yes
Two independent reviewers? | Yes | Study quality appropriately used in analysis? | Yes
Comprehensive literature search? | Yes | Appropriate statistical synthesis? | Yes
All publication types and languages included? | Yes | Publication bias assessed? | No
Included and excluded studies listed? | Yes | Conflicts of interest stated? | Yes
Study characteristics provided? | Yes

A RR <1.0 favors calcium supplementation

B 95% confidence interval

Table 76 Calcium and preeclampsia and other pregnancy outcomes: Characteristics of cohort studies^A,B^

Author Year Study Name Location (Latitude) [PMID] | Population | | Dietary Calcium intake | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Outcomes and Comments
Author Year Study Name Location (Latitude) [PMID] | Population | | Dietary Calcium intake | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV exposure | Lifestyle | Outcomes and Comments
Morris 2007^181^ CPEP reanalysis^C^ US (various) [11262466] | - Health status; - Mean age (SD), y; - Male (%) | Healthy ND 0 | Dietary assessment methodInternal validation? (y/n) | FFQ No | Outcome stratified by total Ca intake quintiles | | X | X | | | X | Total Ca (both)
Oken 2007^182^ Project Viva US (42°N) [17521921] | - Health status; - Mean age (SD), y; - Male (%) | Healthy [most 30 to <40] 0 | Dietary assessment methodInternal validation? (y/n) | FFQ No | Outcome as a function of Ca intake | | X | X | | | | Total Ca (both)

A Both table entries are treated as cohort studies.

B In contrast with most other summary tables of study characteristics, this table is ordered alphabetically by study author.

C Reanalysis of the CPEP trial (calcium versus placebo) for preeclampsia prevention focusing on calcium content in diet (and including the intervention dose in the analyses)

Table 77 Calcium and preeclampsia and other pregnancy outcomes: Results of cohort studies

Author Year Study Name Location (Latitude) [PMID] | Age Range, Sex | Outcome (n/N; Incidence) | Followup Duration | Total Ca Intake, mg/d | No. of Cases | No. in Category | Adjusted OR | 95% CI | P for Trend | Study Quality
Preeclampsia
Morris 2007^181^ CPEP reanalysis US (various) [11262466] | 30–40 y, Women | Preeclampsia (326/4314; 7.6%) | ND | 579 | ND | ND | 1.00 (ref) | | ND | B
Morris 2007^181^ CPEP reanalysis US (various) [11262466] | 30–40 y, Women | Preeclampsia (326/4314; 7.6%) | ND | 580–845 | ND | ND | 0.90 | 0.61, 1.30 | ND | B
Morris 2007^181^ CPEP reanalysis US (various) [11262466] | 30–40 y, Women | Preeclampsia (326/4314; 7.6%) | ND | 846–1131 | ND | ND | 0.95 | 0.65, 1.39 | ND | B
Morris 2007^181^ CPEP reanalysis US (various) [11262466] | 30–40 y, Women | Preeclampsia (326/4314; 7.6%) | ND | 1132–1560 | ND | ND | 0.97 | 0.65, 1.45 | ND | B
Morris 2007^181^ CPEP reanalysis US (various) [11262466] | 30–40 y, Women | Preeclampsia (326/4314; 7.6%) | ND | 1561 | ND | ND | 0.78 | 0.49, 1.24 | ND | B
Oken 2007^182^ Project Viva US (42°N) [17521921] | | Preeclampsia (59/1599; 3.7%)^A^ | | ~1300 | 59 | 1599 | 1.03^B^ | 0.84, 1.27 | NS | B
High blood pressure with or without proteinuria
Morris 2007^181^ CPEP reanalysis US (various) [11262466] | 30–40 y, Women | High blood pressure with or without proteinuria (747/4314; 17.3%) | ND | 579 | ND | ND | 1.00 (ref) | | ND | B
Morris 2007^181^ CPEP reanalysis US (various) [11262466] | 30–40 y, Women | High blood pressure with or without proteinuria (747/4314; 17.3%) | ND | 580–845 | ND | ND | 1.09 | 0.84, 1.42 | ND | B
Morris 2007^181^ CPEP reanalysis US (various) [11262466] | 30–40 y, Women | High blood pressure with or without proteinuria (747/4314; 17.3%) | ND | 846–1131 | ND | ND | 1.10 | 0.83, 1.44 | ND | B
Morris 2007^181^ CPEP reanalysis US (various) [11262466] | 30–40 y, Women | High blood pressure with or without proteinuria (747/4314; 17.3%) | ND | 1132–1560 | ND | ND | 1.14 | 0.85, 1.53 | ND | B
Morris 2007^181^ CPEP reanalysis US (various) [11262466] | 30–40 y, Women | High blood pressure with or without proteinuria (747/4314; 17.3%) | ND | 1561 | ND | ND | 1.35 | 0.98, 1.86 | ND | B
Oken 2007^182^ Project Viva US (42°N) [17521921] | | Pregnancy-induced hypertension (119/1659)^C^ | ND | ~1300 | 119 | 1659 | 0.99 | 0.85, 1.15 | NS | B

A Excludes 119 women with pregnancy-induced hypertension – comparison versus normotensive women

B Per 300 mg of Ca intake (from supplement or diet)

C Excludes 59 women with preeclampsia – comparison versus normotensive women

Relevant published systematic reviews of RCTs (with meta-analyses)

We identified five systematic reviews173–177 (with meta-analyses) of RCTs on calcium supplementation in the first or second trimester versus placebo for the prevention of preeclampsia (Appendix D). We selected a 2006 Cochrane review as eligible for this section.176 All other systematic reviews were covered by the Cochrane review. We did not identify any RCTs published after the Cochrane review was conducted.

Eligible were RCTs comparing at least 1000 mg/d of calcium versus placebo in pregnant women. Studies were performed in several countries (both developed and developing). The review defined preeclampsia as high gestational blood pressure (diastolic blood pressure >90 mmHg, or increase more than 15 mm Hg in diastolic or more than 30 mm Hg in systolic blood pressure) with significant proteinuria (at least 300 mg/d or at least 500 mg).^i^

i Note that a strict definition of preeclampsia requires confirmation of no hypertension or proteinuria outside of pregnancy.

Table 75 summarizes the findings of the Cochrane review. A random effects meta-analysis of all studies suggests that calcium supplementation reduces the risk for preeclampsia (RR=0.48, 95 percent CI 0.33, 0.69). However, there is substantial heterogeneity among the included studies (P<0.001).

In subgroup analyses, the effects of calcium appear larger in women at high risk for hypertension versus women at low risk for hypertension. The same is observed when trials are grouped according to whether women had adequate average calcium intake versus low average calcium intake.

More than 80 percent of the total number of randomized women in this meta-analysis (n=12,914) came from two large trials that reported no significant effects of calcium supplementation for preeclampsia (RR=0.95, 95 percent CI 0.89, 1.05; by fixed effects synthesis). Based on their combined confidence interval, these two studies exclude modest and large effects of calcium for preeclampsia prevention. The remaining (smaller) trials show a protective effect. One of the large RCTs was performed in populations with low background calcium diets178 and the other in populations with adequate background calcium diets.179

Allowing for the above, there is no clear explanation for the observed discrepant findings across the trials in the systematic review. The recurrent pattern is that large trials showed no effect for calcium supplementation, whereas smaller trials showed large effects. Calcium supplementation for preeclampsia prevention is a well known example where large trials and smaller trials show systematically different effects. Past methodological explorations (before the publication of the WHO trial178) have hypothesized that effects may be observed mostly among women with low calcium in their background diet.180 However, as mentioned above, this is not supported by the subgroup analyses.

Cohort studies

We identified two eligible prospective cohort studies (Table 76).181,182 Both were rated B for methodological and reporting quality. The first was a reanalysis of a large RCT and reported no associations of dietary calcium intakes during the first and second trimester with preeclampsia.181 The second study was a prospective cohort that again reported no association between dietary calcium intake in the first trimester and risk of preeclampsia.182 (See Table 77)

Findings by life stage

- 0–6 mo Not applicable
- 7 mo–2 y Not applicable
- 3–8 y Not applicable
- 9–18 y Not applicable
- 19–50 y Not applicable
- 51–70 y Not applicable
- ≥71 y Not applicable
- Postmenopause Not applicable
- Pregnant & lactating women Based on a Cochrane review that synthesized data from 12 RCTs on 15,528 pregnant women, calcium supplementation significantly lowered the risk for preeclampsia during pregnancy. However, this meta-analysis was heterogeneous; significant effects were observed only among small studies, and not in the two largest RCTs that comprised more than 80 percent of the women in the meta-analysis. In addition, two cohort studies found no association between calcium intake and preeclampsia. Overall, the effects of calcium supplementation on preeclampsia are unclear.

#### High blood pressure with or without proteinuria during pregnancy

Synopsis

The synopsis of this outcome is based on the same systematic review described under preeclampsia. Overall, the meta-analysis of 11 RCTs favored calcium supplementation RR = 0.70 (95 percent CI 0.57, 0.86) for the treatment of hypertension during pregnancy, with or without proteinuria. However, there was substantial between-study heterogeneity. (Included in this meta-analysis are the two large trials mentioned in the preeclampsia section, which found no significant effect of calcium supplementation on blood pressure.) The systematic review did not offer a clear explanation for the observed heterogeneity.

Based on the above, there is no clear answer to whether calcium supplementation is effective for preventing high blood pressure (with or without proteinuria) in pregnancy.

Detailed presentation

(Tables 75, 76 & 77)

Relevant published systematic reviews (with meta-analyses)

The Cochrane review that was selected for preeclampsia was applicable for hypertension during pregnancy^i^ as well.176 Table 75 summarizes the findings of the Cochrane review.

i The Cochrane review does not clarify whether the women were confirmed normotensive outside pregnancy. This is why we do not use the term pregnancy-induced hypertension for this outcome.

A meta-analysis of 11 trials (14,946 pregnant women) suggested that calcium supplementation reduces the risk for hypertension during pregnancy (RR=0.70, 95 percent CI 0.57, 0.86). However, there is substantial heterogeneity among the included studies (p<0.001). As described in Table 75, the heterogeneity was not explained by whether the trials included women with low versus adequate background dietary calcium intake.

In subgroup analyses, the effects of calcium appear larger in women at high risk for hypertension versus women at low risk for hypertension. The same is observed when trials are grouped according to whether women had adequate average dietary calcium intake versus low average calcium intake (see Table 75).

Cohort studies

A single prospective cohort study182 (Table 68) reported no association between calcium intake levels and risk for preeclampsia.182 (See Table 69.)

Findings by life stage

- 0–6 mo Not applicable
- 7 mo–2 y Not applicable
- 3–8 y Not applicable
- 9–18 y Not applicable
- 19–50 y Not applicable
- 51–70 y Not applicable
- ≥71 y Not applicable
- Postmenopause Not applicable
- Pregnant & lactating women Based on a Cochrane review that synthesized data from 11 RCTs on 14,946 pregnant women, calcium supplementation significantly lowered the risk for hypertension with or without proteinuria during pregnancy. However, this meta-analysis was very heterogeneous; significant effects were observed only among small studies, and not in the two largest RCTs that comprised more than 80 percent of the women in the meta-analysis. In addition, a cohort study found no association between calcium intake and hypertension during pregnancy. Therefore, the effects of calcium supplementation on hypertension with or without proteinuria during pregnancy are unclear.

#### Preterm birth

Synopsis

The synopsis of this outcome is based on the same systematic review described under preeclampsia. Among 10 RCTs (n=14,751), calcium supplementation has no significant effect on preterm births RR 0.81 (95 percent CI 0.64, 1.03). (Included in this meta-analysis are the two large trials mentioned in the preeclampsia section, which found no significant effects.)

Based on the above, there is no evidence for an effect of calcium supplementation on preterm births.

Detailed presentation

(Table 75)

Relevant published systematic reviews (with meta-analyses)

The Cochrane review that was selected for preeclampsia was applicable for preterm birth as well.176 Table 67 summarizes the findings of the Cochrane review.

A meta-analysis of 10 trials suggests that calcium supplementation had no significant effect on preterm births. There is evidence for between-study heterogeneity in this meta-analysis.

In subgroup analyses, the effects of calcium appear larger in women at high risk for hypertension versus women at low risk for hypertension. The same is observed when trials are grouped according to whether women had low average dietary calcium intake versus adequate average dietary calcium intake.

Findings by life stage

- 0–6 mo Based on a Cochrane review that synthesized data from ten RCTs on 14,751 pregnant women, calcium supplementation had no significant effect on whether infants were born prematurely or not.
- 7 mo–2 y Not applicable
- 3–8 y Not applicable
- 9–18 y Not applicable
- 19–50 y Not applicable
- 51–70 y Not applicable
- ≥71 y Not applicable
- Postmenopause Not applicable
- Pregnant & lactating women Not applicable

#### Small for gestational age infant

Synopsis

The synopsis of this outcome is based on the same systematic review described under preeclampsia. The overall effects of calcium supplementation were not significant (among three RCTs in 13,091 randomized women RR = 1.10, 95 percent CI 0.88, 1.37). (Included in this meta-analysis are the two large trials mentioned in the preeclampsia section, which found no significant effects.)

Based on the above, there is no evidence for an effect of calcium supplementation on preterm births.

Detailed presentation

(Table 75)

Relevant published systematic reviews (with meta-analyses)

The Cochrane review that was selected for preeclampsia was applicable for this outcome as well.176 Table 75 shows that among three trials with pertinent information there was no significant effect of calcium supplementation on the proportion of infants who were small for gestational age.178,179

Findings by life stage

- 0–6 mo Based on a Cochrane review that synthesized data from three RCTs on 13,091 pregnant women, calcium supplementation has no significant effect on whether born infants were small for gestational age or not.
- 7 mo–2 y Not applicable
- 3–8 y Not applicable
- 9–18 y Not applicable
- 19–50 y Not applicable
- 51–70 y Not applicable
- ≥71 y Not applicable
- Postmenopause Not applicable
- Pregnant & lactating women Not applicable

### Calcium and all-cause Mortality

Synopsis

One cohort study (rated B for methodological and reporting quality) reported no significant associations between calcium intakes and all-cause mortality in men or women aged between 40–65 years. No RCTs of calcium intake evaluated all-cause mortality.

Detailed presentation

(Tables 78 & 79)

Table 78 Calcium intake and all-cause mortality: Characteristics of cohort studies

Author Year Study Name Location (Latitude) [PMID] | Population | | Calcium intake | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Study Name Location (Latitude) [PMID] | Population | | Calcium intake | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV exposure | Lifestyle | Comments
Van der Vijver1992^105^ & Slob 1993^126^ Netherlands (52°N) [1544755 & 8478144] | - Health status; - Age range, y; - Male(%) | General population 40–65y 51 | Dietary assessment methodInternal validation? (y/n) | FFQ No | Outcome stratified by total Ca intake quintiles | X | X | X | | | X | Total Ca (food)

Table 79 Calcium intake and all-cause mortality: Results of cohort studies

Author Year Study Name Location (Latitude) [PMID] | Age Range, Sex | Outcome (n/N; Incidence) | Followup Duration | Total Ca Intake, mg/d | No. of Cases | No. in Category | Adjusted OR | 95% CI | P for Trend | Study Quality
Van der Vijver 1992^105^ & Slob1993^126^ Netherlands (52°N) [1544755 & 8478144] | 40–65 y, men | All cause mortality (nd) | 336 mo (28 y) | ≤585 | nd | nd | 1.1 | 0.7, 1.6 | nd | B
Van der Vijver 1992^105^ & Slob1993^126^ Netherlands (52°N) [1544755 & 8478144] | 40–65 y, men | All cause mortality (nd) | 336 mo (28 y) | 585–725 | nd | nd | 1.1 | 0.7, 1.6 | nd | B
Van der Vijver 1992^105^ & Slob1993^126^ Netherlands (52°N) [1544755 & 8478144] | 40–65 y, men | All cause mortality (nd) | 336 mo (28 y) | 725–935 | nd | nd | 0.8 | 0.5, 1.2 | nd | B
Van der Vijver 1992^105^ & Slob1993^126^ Netherlands (52°N) [1544755 & 8478144] | 40–65 y, men | All cause mortality (nd) | 336 mo (28 y) | 935–1245 | nd | nd | 0.9 | 0.6, 1.3 | nd | B
Van der Vijver 1992^105^ & Slob1993^126^ Netherlands (52°N) [1544755 & 8478144] | 40–65 y, men | All cause mortality (nd) | 336 mo (28 y) | >1245 | nd | nd | 1.0 | Reference | nd | B
Van der Vijver 1992^105^ & Slob1993^126^ Netherlands (52°N) [1544755 & 8478144] | 40–65 y, women | All cause mortality (nd) | 336 mo (28 y) | ≤445 | nd | nd | 1.2 | 0.8, 1.9 | nd | B
Van der Vijver 1992^105^ & Slob1993^126^ Netherlands (52°N) [1544755 & 8478144] | 40–65 y, women | All cause mortality (nd) | 336 mo (28 y) | 445–540 | nd | nd | 1.1 | 0.7, 1.7 | nd | B
Van der Vijver 1992^105^ & Slob1993^126^ Netherlands (52°N) [1544755 & 8478144] | 40–65 y, women | All cause mortality (nd) | 336 mo (28 y) | 540–640 | nd | nd | 1.3 | 0.9, 2.0 | nd | B
Van der Vijver 1992^105^ & Slob1993^126^ Netherlands (52°N) [1544755 & 8478144] | 40–65 y, women | All cause mortality (nd) | 336 mo (28 y) | 640–850 | nd | nd | 1.1 | 0.7, 1.7 | nd | B
Van der Vijver 1992^105^ & Slob1993^126^ Netherlands (52°N) [1544755 & 8478144] | 40–65 y, women | All cause mortality (nd) | 336 mo (28 y) | >850 | nd | nd | 1.0 | Reference | nd | B

One cohort study from Amsterdam, Netherlands (52°N), reported in two publications105,126 evaluated associations between calcium intake and all-cause mortality. The cohort was based on a general population health survey and enrolled civil servants or their spouses (aged 40–65 years). The reports received grade “B” for methodological and reporting quality (Table 70).

The publications reported no association between calcium intake and all-cause mortality among men or women. Table 71 shows the results of the various analyses conducted in the two publications.105,126

Findings by life stage

- 0–6 mo No data
- 7 mo–2 y No data
- 3–8 y No data
- 9–18 y No data
- 19–50 y One cohort study found no associations between calcium intakes and all-cause mortality in men or women aged between 40–65 y.
- 51–70 y The above (19–50 y) may be applicable here as well, based on the age range of cohort participants.
- ≥71 y No data
- Postmenopause No data
- Pregnant & lactating women No data

### Calcium and Hypertension and Blood Pressure

We searched for systematic reviews and primary studies that evaluated associations between calcium intake or body stores and incidence of hypertension and change in blood pressure. For the outcome incidence of hypertension, we reviewed randomized controlled trials and other longitudinal studies. For the outcome change in blood pressure, we reviewed only randomized controlled trials. The EPC and the TEP agreed that due to the large volume of literature, the limited resources would not be expended on reviewing observational studies for the surrogate outcome blood pressure. We included only studies of adults. Studies of pregnancy-related hypertension and blood pressure control are included in the pregnancy section.

#### Calcium and hypertension

Synopsis

No systematic reviews evaluated the association between calcium intake and incidence of hypertension. The association has been analyzed in five large studies (6 articles/analyses). No RCTs of calcium intake evaluated hypertension incidence. In analyses of men and women together and of men alone, there was no evidence of an association between calcium intake and risk of hypertension. In the Women’s Health Study (WHS), a highly significant trend was found across quintiles of calcium intake and risk of hypertension, with significantly lower rates of hypertension found among women consuming at least 679 mg calcium per day compared to less than 558 mg calcium per day. The two articles that reported subgroup analyses based on age found associations between lower calcium intake and hypertension among younger adults (below 40 or 50 years of age), but no significant associations in older adults.

Detailed presentation

(Tables 80 & 81 and Figure 21)

Table 80 Calcium and hypertension incidence: Characteristics of cohort studies

Author Year Study Name Location [PMID] | Population | | Dietary Calcium intake | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Study Name Location [PMID] | Population | | Dietary Calcium intake | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV exposure | Lifestyle | Comments
Alonso 2005^183^ U Navarra Follow-up Navarra Spain (43°N) [16280427] | - Health, status; - Mean age (range), y; - Male (%) | Normo-tensive 36 (20–90) 39 | - Dietary assessmentmethod; - Internal validation? (y/n) | FFQ No | Hypertension incidence stratified by total Ca intake quintiles | X | X | X | X | | X | Total Ca (both)
Dwyer 1996^184,A^ NHANES I US (various) [8890661] | - Health status; - Mean age (range), y; - Male (%) | Normo-tensive 46 (25–74) 63 | - Dietary assessment method; - Internal validation? (y/n) | 24 hr recall nd | Hypertension incidence stratified by total Ca intake quartiles | X | X | X | | | X | Total Ca (both)
Ascherio 1992^185^ HPFS US (various) [1330360] | - Health status; - Median age (range), y; - Male (%) | Normo-tensive 50 (40–75) 100 | - Dietary assessment method; - Internal validation? (y/n) | FFQ Yes | Hypertension incidence stratified by total Ca intake categories | | X | X | | | X | Total Ca (both)
Ford 1991^186,B^ NHANES I US (various) [1937662] | - Health status; - Mean age (range), y; - Male (%) | Normo-tensive nd (≥25) 35 | - Dietary assessment method; - Internal validation? (y/n) | nd nd | Hypertension incidence stratified by total Ca intake quartiles | X | X | | | | | Total Ca (both)
Wang 2008^187^ WHS US (various) [18259007] | - Health status; - Mean age (SD, range), y; - Male (%) | Normo-tensive 54 (6.5; ≥45) 0 | - Dietary Assessment method; - Internal validation? (y/n) | FFQ No | Hypertension incidence stratified by total Ca intake quintiles | X | X | X | X | | X | Total Ca (both)
Ascherio 1996^188^ NHS US (various) [8621198] | - Health status; - Mean age (range), y; - Male (%) | Normo-tensive nd (30–55) 0 | - Dietary assessment method; - Internal validation? (y/n) | FFQ Yes | Hypertension incidence stratified by total Ca intake categories | | X | X | | | X | Total Ca (both)

A Overall and age subgroup analyses from NHANES I reported in this study. However, different samples selected; 63% male.

B Sex and race subgroup analyses from NHANES I reported in this study. However, different samples selected; 35% male.

Table 81 Calcium and hypertension incidence: Results of cohort studies

Author Year Study Name [PMID] | Age Range, Sex | Outcome (n/N, Incidence) | Followup Duration (Time to Dx) | Total Ca Intake, mg/day | No. of Cases | No. in Category | Adjusted OR | 95% CI | P for Trend | Study Quality
Both Sexes
Alonso 2005^183^ U Navarra Follow-up [16280427] | 20–90 y, Both | Hypertension (180/6686, 0.027) | 2 y | Mean (SD) (200) | 39 | ~1337 | 1 | Reference | 0.67 | C
Alonso 2005^183^ U Navarra Follow-up [16280427] | 20–90 y, Both | Hypertension (180/6686, 0.027) | 2 y | 1000 (200) | 39 | ~1337 | 0.98 | 0.62, 1.54 | 0.67 | C
Alonso 2005^183^ U Navarra Follow-up [16280427] | 20–90 y, Both | Hypertension (180/6686, 0.027) | 2 y | 1200 (200) | 35 | ~1337 | 0.82 | 0.51, 1.30 | 0.67 | C
Alonso 2005^183^ U Navarra Follow-up [16280427] | 20–90 y, Both | Hypertension (180/6686, 0.027) | 2 y | 1400 (300) | 30 | ~1337 | 0.73 | 0.45, 1.19 | 0.67 | C
Alonso 2005^183^ U Navarra Follow-up [16280427] | 20–90 y, Both | Hypertension (180/6686, 0.027) | 2 y | 1700 (400) | 37 | ~1337 | 0.97 | 0.61, 1.54 | 0.67 | C
Dwyer 1996^184,A^ NHANES I [8890661] | 25–74 y, Both | Hypertension, treated (1704/6634, 0.257) | 10 y | nd | nd | ~1658 | 29.8% | | nd | C
Dwyer 1996^184,A^ NHANES I [8890661] | 25–74 y, Both | Hypertension, treated (1704/6634, 0.257) | 10 y | nd | nd | ~1658 | ~27% | | nd | C
Dwyer 1996^184,A^ NHANES I [8890661] | 25–74 y, Both | Hypertension, treated (1704/6634, 0.257) | 10 y | nd | nd | ~1658 | ~25% | | nd | C
Dwyer 1996^184,A^ NHANES I [8890661] | 25–74 y, Both | Hypertension, treated (1704/6634, 0.257) | 10 y | nd | nd | ~1658 | 21.3% | | nd | C
Dwyer 1996^184,A^ NHANES I [8890661] | ≤40 y | Hypertension, treated (nd/nd) | 10 y | nd | nd | nd | 1 | Reference | nd | C
Dwyer 1996^184,A^ NHANES I [8890661] | ≤40 y | Hypertension, treated (nd/nd) | 10 y | nd | nd | nd | 0.70 | 0.54, 0.91^C^ | nd | C
Dwyer 1996^184,A^ NHANES I [8890661] | ≤40 y | Hypertension, treated (nd/nd) | 10 y | nd | nd | nd | 0.79 | 0.66, 0.94^C^ | nd | C
Dwyer 1996^184,A^ NHANES I [8890661] | ≤40 y | Hypertension, treated (nd/nd) | 10 y | nd | nd | nd | 0.89 | 0.81, 0.97^C^ | nd | C
Dwyer 1996^184,A^ NHANES I [8890661] | >40 y | Hypertension, treated (nd/nd) | 10 y | nd | nd | nd | 1 | Reference | nd | C
Dwyer 1996^184,A^ NHANES I [8890661] | >40 y | Hypertension, treated (nd/nd) | 10 y | nd | nd | nd | 1.01 | 0.94, 1.08 | nd | C
Dwyer 1996^184,A^ NHANES I [8890661] | >40 y | Hypertension, treated (nd/nd) | 10 y | nd | nd | nd | 1.02 | 0.89, 1.18 | nd | C
Dwyer 1996^184,A^ NHANES I [8890661] | >40 y | Hypertension, treated (nd/nd) | 10 y | nd | nd | nd | 1.04 | 0.84, 1.28 | nd | C
Men
Ascherio 1992^185^ HPFS [1330360] | 40–75 y, Men | Hypertension (1248/30,681, 0.041) | 4 y | <500 | 85 | 1677 | 1.17 | 0.91, 1.50 | 0.53 | B
Ascherio 1992^185^ HPFS [1330360] | 40–75 y, Men | Hypertension (1248/30,681, 0.041) | 4 y | 500–700 | 297 | 7504 | 0.91 | 0.77, 1.07 | 0.53 | B
Ascherio 1992^185^ HPFS [1330360] | 40–75 y, Men | Hypertension (1248/30,681, 0.041) | 4 y | 700–900 | 333 | 8576 | 0.89 | 0.76, 1.04 | 0.53 | B
Ascherio 1992^185^ HPFS [1330360] | 40–75 y, Men | Hypertension (1248/30,681, 0.041) | 4 y | 900–1100 | 195 | 5038 | 0.91 | 0.76, 1.09 | 0.53 | B
Ascherio 1992^185^ HPFS [1330360] | 40–75 y, Men | Hypertension (1248/30,681, 0.041) | 4 y | ≥1100 | 338 | 7890 | 1 | Reference | 0.53 | B
Ascherio 1992^185^ HPFS [1330360] | ≤50 y | Hypertension (nd/14,354) | 4 y | <500 | nd | nd | 1.52 | nd^*^ | nd | B
Ascherio 1992^185^ HPFS [1330360] | ≤50 y | Hypertension (nd/14,354) | 4 y | 500–1100 | nd | nd | 0.86 | nd | nd | B
Ascherio 1992^185^ HPFS [1330360] | ≤50 y | Hypertension (nd/14,354) | 4 y | ≥1100 | nd | nd | 1 | Reference | nd | B
Ascherio 1992^185^ HPFS [1330360] | >50 y | Hypertension (nd/16,314) | 4 y | <500 | nd | nd | 0.98 | nd | | B
Ascherio 1992^185^ HPFS [1330360] | >50 y | Hypertension (nd/16,314) | 4 y | 500–1100 | nd | nd | 0.91 | nd | | B
Ascherio 1992^185^ HPFS [1330360] | >50 y | Hypertension (nd/16,314) | 4 y | ≥1100 | nd | nd | 1 | Reference | | B
Ford 1991^186,B^ NHANES I [937662] | ≥25 y, Men (White) | Hypertension (360/1707, 0.211) | 10 y | <344 | 47 | ~215 | 1 | Reference | nd | C
Ford 1991^186,B^ NHANES I [937662] | ≥25 y, Men (White) | Hypertension (360/1707, 0.211) | 10 y | 344–591 | 78 | ~382 | 0.91 | 0.60, 1.38 | nd | C
Ford 1991^186,B^ NHANES I [937662] | ≥25 y, Men (White) | Hypertension (360/1707, 0.211) | 10 y | 591–954 | 104 | ~448 | 1.09 | 0.73, 1.63 | nd | C
Ford 1991^186,B^ NHANES I [937662] | ≥25 y, Men (White) | Hypertension (360/1707, 0.211) | 10 y | >954 | 131 | ~662 | 0.96 | 0.64, 1.45 | nd | C
Ford 1991^186,B^ NHANES I [937662] | ≥25 y, Men (Black) | Hypertension (64/183, 0.350) | 10 y | <344 | 20 | ~34 | 1 | Reference | nd | C
Ford 1991^186,B^ NHANES I [937662] | ≥25 y, Men (Black) | Hypertension (64/183, 0.350) | 10 y | 344–591 | 17 | ~45 | 0.68 | 0.28, 1.65 | nd | C
Ford 1991^186,B^ NHANES I [937662] | ≥25 y, Men (Black) | Hypertension (64/183, 0.350) | 10 y | 591–954 | 18 | ~56 | 0.54 | 0.22, 1.33 | nd | C
Ford 1991^186,B^ NHANES I [937662] | ≥25 y, Men (Black) | Hypertension (64/183, 0.350) | 10 y | >954 | 9 | ~34 | 0.35 | 0.11, 1.13 | nd | C
Women
Wang 2008^187^ WHS [8259007] | ≥45 y, Women | Hypertension (8529/28, 886, 0.295) | 10 y | 189–557 | 1860 | 5777 | 1 | Reference | <0.0001 | A
Wang 2008^187^ WHS [8259007] | ≥45 y, Women | Hypertension (8529/28, 886, 0.295) | 10 y | 558–678 | 1778 | 5777 | 0.96 | 0.90, 1.03 | <0.0001 | A
Wang 2008^187^ WHS [8259007] | ≥45 y, Women | Hypertension (8529/28, 886, 0.295) | 10 y | 679–801 | 1626 | 5777 | 0.89 | 0.83, 0.95^C^ | <0.0001 | A
Wang 2008^187^ WHS [8259007] | ≥45 y, Women | Hypertension (8529/28, 886, 0.295) | 10 y | 802–999 | 1634 | 5777 | 0.89 | 0.83, 0.95^C^ | <0.0001 | A
Wang 2008^187^ WHS [8259007] | ≥45 y, Women | Hypertension (8529/28, 886, 0.295) | 10 y | 1000–2559 | 1631 | 5777 | 0.87 | 0.81, 0.93^C^ | <0.0001 | A
Ascherio 1996^188^ NHS [621198] | 30–55 y, Women | Hypertension (2526/41, 541, 0.061) | 14 y | <400 | 87 | 5581 person-y | 1 | Reference | 0.76 | B
Ascherio 1996^188^ NHS [621198] | 30–55 y, Women | Hypertension (2526/41, 541, 0.061) | 14 y | 400–600 | 608 | 36,605 | 1.07 | 0.85, 1.35 | 0.76 | B
Ascherio 1996^188^ NHS [621198] | 30–55 y, Women | Hypertension (2526/41, 541, 0.061) | 14 y | 600–800 | 712 | 42,544 | 1.05 | 0.83, 1.31 | 0.76 | B
Ascherio 1996^188^ NHS [621198] | 30–55 y, Women | Hypertension (2526/41, 541, 0.061) | 14 y | 800–1000 | 407 | 24,240 | 1.03 | 0.82, 1.31 | 0.76 | B
Ascherio 1996^188^ NHS [621198] | 30–55 y, Women | Hypertension (2526/41, 541, 0.061) | 14 y | ≥1000 | 712 | 41,325 | 1.04 | 0.83, 1.31 | 0.76 | B
Ford 1991^186,B^ NHANES I [937662] | ≥25 y, Women (White) | Hypertension (645/3065, 0.210) | 10 y | <344 | 186 | ~865 | 1 | Reference | nd | C
Ford 1991^186,B^ NHANES I [937662] | ≥25 y, Women (White) | Hypertension (645/3065, 0.210) | 10 y | 344–591 | 183 | ~806 | 1.11 | 0.87, 1.43 | nd | C
Ford 1991^186,B^ NHANES I [937662] | ≥25 y, Women (White) | Hypertension (645/3065, 0.210) | 10 y | 591–954 | 172 | ~775 | 1.17 | 0.90, 1.51 | nd | C
Ford 1991^186,B^ NHANES I [937662] | ≥25 y, Women (White) | Hypertension (645/3065, 0.210) | 10 y | >954 | 104 | ~619 | 1.01 | 0.74, 1.38 | nd | C
Ford 1991^186,B^ NHANES I [937662] | ≥25 y, Women (Black) | Hypertension (171/456, 0.375) | 10 y | <344 | 94 | ~225 | 1 | Reference | nd | C
Ford 1991^186,B^ NHANES I [937662] | ≥25 y, Women (Black) | Hypertension (171/456, 0.375) | 10 y | 344–591 | 35 | ~120 | 0.61 | 0.37, 1.01 | nd | C
Ford 1991^186,B^ NHANES I [937662] | ≥25 y, Women (Black) | Hypertension (171/456, 0.375) | 10 y | 591–954 | 31 | ~74 | 1.11 | 0.62, 2.01 | nd | C
Ford 1991^186,B^ NHANES I [937662] | ≥25 y, Women (Black) | Hypertension (171/456, 0.375) | 10 y | >954 | 11 | ~37 | 0.77 | 0.33, 1.81 | nd | C

* Statistically significant (P<0.05)

A Overall and age subgroup analyses from NHANES I reported in this study. However, different samples selected; 63% male.

B Sex and race subgroup analyses from NHANES I reported in this study. However, different samples selected; 35% male.

C Estimated from available data

Figure 21 Hypertension risk stratified by calcium intake

The six articles, reporting investigations of five studies, included two analyses of combined men and women in the NHANES I study and Navarra, Spain (both methodological quality C),183,184 two analyses of men alone in the Health Professionals Follow-up Study (HPFS) and NHANES I (of methodological quality B and C, respectively), 185,186 and three analyses of women alone in the WHS, the Nurses Health Study (NHS), and NHANES I (of methodological quality A, B, and C, respectively).186–188 All studies included only people without hypertension at baseline. Only the A quality analysis, WHS, included elevated blood pressure in their outcome definition of hypertension; all other analyses used self-reported hypertension (generally based on a physician’s diagnosis or treatment). The mean ages of the participants varied widely across studies (36–54 years) among those that reported mean data; the range of ages within studies varied from broad (20–90 years) to narrow (30–55 years) among those that reported ranges. All studies reported adjusted analyses; though each adjusted for different factors. Most of the studies were limited by such factors as reliance on self-reported hypertension (without assessment of blood pressure), exclusion of numerous participants due to lack of data, inadequate reporting of results data, and lack of reporting of definitions (ranges or averages of calcium quintiles).

Two studies reported analyses for combined men and women. These are discussed here. The remaining analyses of men or women separately are discussed below. In analyses of combined men and women (each with almost 7000 participants), neither study reported a significant association. No significant trend or individual analyses of quintiles was found in the short duration (2 years) Spanish cohort study. A poorly reported analysis from NHANES I concluded that there was progressively higher incidence of hypertension in lower quartiles of calcium intake after 10 years, but no statistical analysis was performed and the definitions of the quartiles were not provided.

Findings per calcium intake level

Among the studies that provided definitions of the compared categories of calcium intake, consistent significant associations were found for calcium intakes below 500 mg/day in men under age 50 years (compared to over 1100 mg/day) and below 558 mg/day in women (compared to over 678 mg/day).

Findings per age and sex

Men alone were analyzed from the PHFS (about 31,000 men) and NHANES I (about 2000 men, split by race). Neither analysis found a significant trend or any significant differences among different calcium intake categories at 4 and 10 years, respectively for the two studies.

Women alone were analyzed from three studies. The studies had heterogeneous findings. The A quality analysis of the WHS (about 29,000 women) found a highly significant trend across quintiles (P<0.0001) at 10 years with a significantly higher rate of hypertension in women in the lowest calcium intake quintile (189–557 mg/day) compared to all quintiles with intakes above 679 mg/day. However, the B quality analysis of the NHS (about 41,500 women) found no significant association by calcium intake at 14 years and the C quality analysis of NHANES I (about 3500 women, split by race) found no consistent association at 10 years.

One C quality analysis of NHANES I assessed subgroups of combined men and women by age (divided at 40 years old). Among people under age 40 years, those in the lowest quartile of calcium intake had significantly higher rates of being treated for hypertension after 10 years; however, the article failed to define the calcium intake quartiles. No significant association was found among older participants. In the HPFS, in men under age 50 years, a higher rate of hypertension at 4 years was found in those with calcium intake less than 500 mg/d compared to over 1100 mg/d; but no association was found in older men.

Findings by life stage

- 0–6 mo Not reviewed
- 7 mo–2 y Not reviewed
- 3–8 y Not reviewed
- 9–18 y Not reviewed
- 19–50 y Five of the six studies included mostly people within this life stage.183–186,188 Overall, there was no evidence of a significant association between calcium intake and risk of hypertension. However, as described in detail in the Findings per age and sex section above, in two subgroup analyses, significant associations were found between the lowest category of calcium intake and increased risk of hypertension in younger people (under age 40 – calcium intake range not reported, or age 50 years – less than 500 mg/d compared to over 1100 mg/d.
- 51–70 y Four of the six studies included people largely within this life stage.184,185,187,188 The studies mostly found no significant associations between calcium intake and risk of hypertension, including within the 2 subgroups of adults above 40 or 50 years of age. However, the WHS, which included women mostly within this life stage, found a highly significant trend across quintiles (P<0.0001) at 10 years with a significantly higher rate of hypertension in women in the lowest calcium intake quintile (189–557 mg/d) compared to all quintiles with intakes above 679 mg/d.
- ≥71 y Few of the people in the studies appear to have been in this life stage. No unique conclusions are possible for this life stage separate from those for people 51 to 70 years.
- Postmenopause Only the WHS appeared to have included (or analyzed) primarily postmenopausal women. The study found a highly significant trend across quintiles (P<0.0001) at 10 years with a significantly higher rate of hypertension in women in the lowest calcium intake quintile (189–557 mg/d) compared to all quintiles with intakes above 679 mg/d.
- Pregnant & lactating women Not reviewed

#### Calcium and blood pressure

Synopsis

We identified six systematic reviews that evaluated RCTs of calcium intake and changes in blood pressure. Five additional trials not identified by these systematic reviews met eligibility criteria for this report and are summarized together with the systematic reviews. Altogether, 69 trials have been identified. The range of intervention calcium doses were approximately 400 to 2000 mg/d, with most studies using 1000 to 1500 mg/d. The systematic reviews followed the patterns of the primary studies in that they were divided among those that focused on studies of people without hypertension, people with hypertension, and general populations (with or without hypertension, without subgroup analyses). Because the systematic reviews all used somewhat different eligibility criteria, they included overlapping groups of trials. No one or two systematic reviews captured most of the relevant trials; therefore, all systematic reviews are included here.

Two overlapping systematic reviews evaluated trials of normotensive individuals. Both found no significant effect of calcium supplementation and blood pressure. The two additional, more recent primary studies of normotensive participants were consistent with this finding.

Four overlapping systematic reviews of the effect of calcium on blood pressure in hypertensive individuals mostly found significant effects on systolic blood pressure (ranging from about −2 to −4 mm Hg). An older, highly selective systematic review found no significant effect. The systematic review that found the largest effect of calcium on systolic blood pressure also found a significant effect on diastolic blood pressure (−1.5 mm Hg), but the other systematic reviews found no significant effect. None of the more recent primary studies were in people exclusively with hypertension.

Four of the systematic reviews performed meta-analyses of all people regardless of hypertension diagnosis. Except for the oldest, highly selective systematic review, they found significant effects on systolic blood pressure (ranging from −1.9 to −0.9 mm Hg). The summary estimates of the effect on diastolic blood pressure ranged from −1.0 to +0.03 mm Hg, which were mostly nonsignificant. The individual, recent primary studies of mixed populations (in terms of hypertension) found larger, though statistically nonsignificant, effects.

The systematic reviews that evaluated factors including age, sex, calcium dose, background dietary calcium, supplement versus dietary source, and other factors found no significant associations (or differences). The five additional primary studies did not provide further insights into these subgroup analyses.

Detailed presentation

(Tables 82, 83, & 84)

Table 82 Summary of systematic reviews of calcium and blood pressure

Author Year [PMID] | Griffith 1999^189^ [10075392]
Design (Search Years) | Randomized controlled trials (1966–1997)
Population | Both hypertensive and normotensive participants
Intervention and Comparator | Dietary and nondietary calcium supplementation versus placebo (no supplement) Dose range 600–2000 mg (36% 1000 mg; 26% 1500–1600 mg; 12% 2000 mg)
Results | 42 trials SBP: −1.44 (−2.20, −0.68)^A^; statistically heterogeneous DBP: −0.84 (−1.44, −0.24); statistically heterogeneous Subgroup analyses did not find that heterogeneity could be explained by age, sex, baseline calcium, dietary versus nondietary calcium, or quality. Subgroups with hypertensive versus normotensive people were significantly different (no further details). Conclusions similar to previous systematic review (Bucher 1996^191^)
Comments | Update of Bucher 1996^191^ (see below).
AMSTAR
A priori design? | Yes | Study quality assessment performed? | Yes
Two independent reviewers? | Yes | Study quality appropriately used in analysis? | No
Comprehensive literature search? | Yes | Appropriate statistical synthesis? | Yes
All publication types and languages included? | Yes | Publication bias assessed? | No
Included and excluded studies listed? | Yes | Conflicts of interest stated? | No
Study characteristics provided? | Yes | Study quality not discussed in conclusions. Funding source reported, but not conflict of interest.
Author Year [PMID] | van Mierlo 2006^190^ [16673011]
Design (Search Years) | Randomized controlled trials (1966–2003)
Population | Both hypertensive and normotensive participants
Intervention and Comparator | Calcium supplementation versus placebo (no supplement) Dose range 355–2000 mg (40% 1000 mg; 32% 1500–1600 mg; 6% 2000 mg)
Results | 40 trials SBP: −1.86 (95% CI −2.91, −0.81); statistically heterogeneous DBP: −0.99 (95% CI −1.61, −0.37); statistically heterogeneous In multivariable analysis including age, sex, initial calcium intake, calcium dose, and initial blood pressure:
Results | | SBP | DBP
Results | Age <45 y | −1.45 (−2.99, +0.09) | −1.26 (−2.20, −0.33)
Results | ≥45 y | −2.33 (−3.69, −0.96) | −0.80 (−1.62, +0.02)
Results | Male ≤50% | −2.20 (−3.68, −0.72) | −1.12 (−1.98, −0.26)
Results | >50% | −1.77 (−3.13, −0.42) | −0.84 (−1.65, −0.04)
Results | Initial BP <140/90 mm Hg | −2.04 (−3.40, −0.68) | −1.04 (−1.86, −0.22)
Results | ≥140/90 mm Hg | −1.85 (−3.45, −0.32) | −0.89 (−1.79, +0.01)
Results | Ca dose ≤1000 mg | −2.17 (−3.59, −0.75) | −1.41 (−2.24, −0.59)
Results | >1000 mg | −1.75 (−3.20, −0.31) | −0.56 (−1.40, +0.29)
Results | Blood pressures not statistically significantly different between any strata.
Comments
AMSTAR
A priori design? | Yes | Study quality assessment performed? | Yes
Two independent reviewers? | Yes | Study quality appropriately used in analysis? | No
Comprehensive literature search? | Yes | Appropriate statistical synthesis? | Yes
All publication types and languages included? | Unclear | Publication bias assessed? | Yes
Included and excluded studies listed? | Partial | Conflicts of interest stated? | Yes
Study characteristics provided? | Yes | No data on inclusion of unpublished data. Excluded studies available from authors
Author Year [PMID] | Bucher 1996^191^ [8596234]
Design (Search Years) | Randomized controlled trials (1966–1994)
Population | Both hypertensive and normotensive participants
Intervention and Comparator | Dietary and nondietary calcium supplementation vs. placebo (no supplement) Dose range 406–2000 mg (41% 1000 mg; 31% 1500–1600 mg; 8% 2000 mg)
Results | 33 trials [Overall summary results were updated in Griffith 1999^189^, above] Studies with specified subgroups of hypertensive and normotensive participants (6 trials):
Results | Hypertensives | SBP −4.30 (−6.47, −2.13) | DBP −1.50 (−2.77, −0.23)
Results | Normotensives | SBP −0.27 (−1.80, +1.27) | DBP −0.33 (−1.56, +0.90)
Results | Regression analyses:
Results | BP (continuous scale) | SBP OR = 0.99 (0.96, 1.01) | DBP OR = 0.99 (0.96, 1.03)
Results | Dose of calcium, duration of supplementation, dietary vs. nondietary calcium supplementation, methodological quality did not demonstrate a relationship with the magnitude of treatment effect.
Comments | Updated in Griffith 1999^189^ (see above)
AMSTAR
A priori design? | Yes | Study quality assessment performed? | Yes
Two independent reviewers? | Yes | Study quality appropriately used in analysis? | Yes
Comprehensive literature search? | Yes | Appropriate statistical synthesis? | Yes
All publication types and languages included? | Yes | Publication bias assessed? | No
Included and excluded studies listed? | Yes | Conflicts of interest stated? | No
Study characteristics provided? | Yes | Funding source reported, but not conflict of interest.
Author Year [PMID] | Allender 1996^192^ [8610952]
Design (Search Years) | Randomized controlled trials (1982–1993)
Population | Both hypertensive and normotensive participants
Intervention and Comparator | Dietary and nondietary calcium supplementation vs. placebo (no supplement) Dose range 400–2160 mg (35% 1000 mg; 29% 1500–1600 mg; 10% 2000 mg)
Results | 26 trials (22 trials included in meta-analyses) SBP: −0.89 (−1.74, −0.05) DBP: −0.18 (−0.75, +0.40)
Results | Hypertensives | SBP −1.68 (−3.18, −0.18) | DBP +0.02 (−0.96, +1.00)
Results | Normotensives | SBP −0.53 (−1.56, +0.49) | DBP −0.28 (−0.99, +0.42)
Results | By weighted linear regression analyses, age, sex, calcium dose, trial duration were not associated with treatment effect (P>0.10)
Comments
AMSTAR
A priori design? | Yes | Study quality assessment performed? | No
Two independent reviewers? | Yes | Study quality appropriately used in analysis? | No
Comprehensive literature search? | Yes | Appropriate statistical synthesis? | No
All publication types and languages included? | Yes | Publication bias assessed? | No
Included and excluded studies listed? | No | Conflicts of interest stated? | No
Study characteristics provided? | Yes | Excluded studies not enumerated or listed. Fixed effects models used.
Author Year [PMID] | Cappuccio 1989^193^ [2697729]
Design (Search Years) | Randomized controlled trials (1983–1988)
Population | Both hypertensive and normotensive participants
Intervention and Comparator | Nondietary calcium supplementation versus placebo (no supplement) or low calcium intake Dose range 800–1600 mg (60% 1000 mg; 27% 1500–1600 mg)
Results | 15 trials SBP (supine): −0.13 (−0.46, +0.19) DBP (supine): +0.03 (−0.17, +0.22)
Results | Hypertensives | SBP +0.06 (−0.59, +0.72) | DBP +0.03 (−0.21, +0.27)
Comments
AMSTAR
A priori design? | Yes | Study quality assessment performed? | No
Two independent reviewers? | nd | Study quality appropriately used in analysis? | NA
Comprehensive literature search? | Yes | Appropriate statistical synthesis? | No
All publication types and languages included? | nd | Publication bias assessed? | No
Included and excluded studies listed? | No | Conflicts of interest stated? | No
Study characteristics provided? | Yes | Excluded studies not enumerated or listed. Fixed effects models used.
Author Year [PMID] | Dickinson 2006^198^ [16625609]^B^
Design (Search Years) | Randomized controlled trials (1982–2003/2005^C^)
Population | Hypertensive participants
Intervention and Comparator | Dietary and nondietary calcium supplementation versus placebo (no supplement) Dose range 400–2000 mg (50% 1000 mg; 25% 1500–1600 mg; 6% 2000 mg)
Results | 13 trials SBP: −2.53 (−4.45, −0.60); statistically heterogeneous DBP: −0.81 (−2.07, +0.44); statistically heterogeneous
Results | Ca dose <1200 mg | SBP −2.67 (−5.15, −0.18) | DBP −0.75 (−2.13, +0.63)
Results | Ca dose 1200−2000 mg | SBP −2.69 (−5.86, +0.47) | DBP −0.78 (−3.82, +2.25)
Results | Not statistically significantly different by calcium dose
Comments
AMSTAR
A priori design? | Yes | Study quality assessment performed? | Yes
Two independent reviewers? | Yes | Study quality appropriately used in analysis? | Yes
Comprehensive literature search? | Yes | Appropriate statistical synthesis? | Yes
All publication types and languages included? | Yes | Publication bias assessed? | Yes
Included and excluded studies listed? | Yes | Conflicts of interest stated? | Yes
Study characteristics provided? | Yes

A Numbers in parentheses are 95% confidence intervals

B A technical update, with no further studies added was published in the Cochrane database in 2008.

C Different dates for different databases.

Table 83 Calcium and blood pressure: Characteristics of RCTs

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Whelton 1997^195^ TOHP US (various) [9022561] | - Health status; - Mean age (range), y; - Male (%) | No HTN (DBP80–89 mm Hg) 43 (30–54) 68 | nd | Calcium supplement vs. Placebo | nd
Lijnen 1995^197^ Leuven, Belgium (51°N) [8557965] | - Health status; - Mean age (range), y; - Male (%) | Normotensive 24 (20–44) 100 | “Low calcium diet” run-in | Calcium supplement vs. Placebo | nd | With low dairy intake
Reid 2005^194^ Auckland, New Zealand (36.5°S) [15827103] | - Health status; - Mean age(range), y; - Male (%) | Healthy 75(≥55) 0 | Ca 857 mg/day | Calcium supplement vs. Placebo | Calcium group: 55%, Placebo group: 58%
Ghadirian 1995^120^ Montreal, Canada (46°N) [7493659] | - Health status; - Mean age (range), y; - Male (%) | Healthy ~80 (≥50) 0 | Ca 776 mg/day | Dairy vs. Dairy-free intake | Non-compliant and those who provided incomplete data were excluded.
Hatton 2003^196^ CPEP Portland, Oregon (45.5°N) [14553957] | - Health status; - Mean age (range/SD), y; - Male (%) | Pregnant during trial nd 0 | nd | Calcium supplement vs. Placebo (both on prenatal vitamins including Vit D_2_ 400 IU) | nd (but all had to meet a compliance test prior to randomization) | Oregon site only. Post- pregnancy followup

Table 84 Calcium and blood pressure: Results of RCTs

Author Year Study Name [PMID] | Age Range, Sex; Population | Outcome | 1°/2° | Mean Followup, unit | Interventions, Daily Dose | No. Analyzed | Unit | Baseline | Change | Change 95% CI | Net Diff | Net Diff 95% CI | P Btw | Study Quality
SYSTOLIC BLOOD PRESSURE
Normotensive
Whelton1997^195^ TOHP [9022561] | 30–54 y, Both; No HTN(DBP 80–89 mm Hg) | SBP | 1° | 18 mo | Ca carbonate1000 mg | 221 | mm Hg | 126.0 | nd | nd | ~−0.5^A^ | ~−2, −1 | NS | C
Whelton1997^195^ TOHP [9022561] | 30–54 y, Both; No HTN(DBP 80–89 mm Hg) | SBP | 1° | 18 mo | Placebo | 224 | | 125.4 | nd | nd | | | | C
Lijnen 1995^197^ Belgium [8557965] | 20–44 y, Men No HTN | SBP, supine | 2° | 4 mo | Ca gluconate 2000 mg (low dairy intake) | 16 | mm Hg | 114 | ~−4^A^ | nd | ~−2 | nd | NS | C
Lijnen 1995^197^ Belgium [8557965] | 20–44 y, Men No HTN | SBP, supine | 2° | 4 mo | Placebo (low dairy intake) | 16 | | 114 | ~−2 | nd | | | | C
All women
Reid 2005^194^ New Zealand [15827103] | ≥55 y, Women; All BP | SBP | 2° | 30 mo | Ca citrate1000 mg | 732 | mm Hg | 134.9 | 0.0 | −0.1, 0.1 | −2.4 | −0.8, 5.6 | 0.14 | B
Reid 2005^194^ New Zealand [15827103] | ≥55 y, Women; All BP | SBP | 2° | 30 mo | Placebo | 739 | | 133.9 | +2.4 | 2.3, 2.5 | | | | B
Ghadirian 1995^120^ Canada [7493659] | ≥50 y, Women; All BP | SBP | 2° | 1 mo | Dairy intake (1242 mg Ca) | 81 | mm Hg | 140.34 | −2.69 | −7.3, 2.0* | −5.4 | −12.3, 1.4^C^ | NS | C
Ghadirian 1995^120^ Canada [7493659] | ≥50 y, Women; All BP | SBP | 2° | 1 mo | Dairy-free (377 mg Ca) | 77 | | 131.71 | +2.75 | −2.3, 7.8* | | | | C
Hatton 2003^196^ CPEP [14553957] | Pregnant, Women^B^; All BP | SBP | 2° | 2 y post-partum | Ca carbonate 2000 mg (+Vit D_2_ 400 IU) | 37 | mm Hg | nd | | Final 101.9 | Difference −2.2 | −7.8, 3.4^C^ | NS | C
Hatton 2003^196^ CPEP [14553957] | Pregnant, Women^B^; All BP | SBP | 2° | 2 y post-partum | Placebo (+Vit D_2_ 400 IU) | 25 | | nd | | 104.1 | | | | C
DIASTOLIC BLOOD PRESSURE
Normotensive
Whelton1997^195^ TOHP [9022561] | 30–54 y, Both; No HTN (DBP 80–89 mm Hg) | DBP | 1° | 18 mo | Ca carbonate1000 mg | 221 | mm Hg | 84.1 | nd | nd | ~+0.35^A^ | ~−1, 1 | NS | C
Whelton1997^195^ TOHP [9022561] | 30–54 y, Both; No HTN (DBP 80–89 mm Hg) | DBP | 1° | 18 mo | Placebo | 224 | | 83.9 | nd | nd | | | | C
Lijnen 1995^197^ Belgium [8557965] | 20–44 y, Men No HTN | DBP, supine | 2° | 4 mo | Ca gluconate 2000 mg (low dairy intake) | 16 | mm Hg | 74 | ~−1^A^ | nd | ~−1 | nd | NS | C
Lijnen 1995^197^ Belgium [8557965] | 20–44 y, Men No HTN | DBP, supine | 2° | 4 mo | Placebo (low dairy intake) | 16 | | 72 | ~0 | nd | | | | C
All women
Reid 2005^194^ New Zealand [15827103] | ≥55 y, Women; All BP | DBP | 2° | 30 mo | Ca citrate 1000 mg | 732 | mm Hg | 70.1 | −0.2 | −0.2, −0.2 | −1.0 | −2.3, 0.3 | 0.13 | B
Reid 2005^194^ New Zealand [15827103] | ≥55 y, Women; All BP | DBP | 2° | 30 mo | Placebo | 739 | | 69.6 | +0.8 | 0.8, 0.8 | | | | B
Ghadirian 1995^120^ Canada [7493659] | ≥50 y, Women; All BP | DBP | 2° | 1 mo | Dairy intake (1242 mg Ca) | 81 | mm Hg | 81.17 | −7.78 −5.59 | −10.0, −5.5* | −2.2 | −5.4, 1.0^C^ | NS | C
Ghadirian 1995^120^ Canada [7493659] | ≥50 y, Women; All BP | DBP | 2° | 1 mo | Dairy-free (377 mg Ca) | 77 | | 79.09 | | −7.9, −3.3* | | | | C
Hatton 2003^196^ CPEP [14553957] | Pregnant, Women^B^; All BP | DBP | 2° | 2 y post- partum | Ca carbonate 2000 mg (+Vit D_2_ 400 IU) | 37 | mm Hg | nd | | Final 67.1 | Difference −0.7 | −4.8, 3.4 | NS | C
Hatton 2003^196^ CPEP [14553957] | Pregnant, Women^B^; All BP | DBP | 2° | 2 y post- partum | Placebo (+Vit D_2_ 400 IU) | 25 | | nd | | 67.8 | | | | C

A From figure

B Blood pressure outcomes are 1 year post-partum

C Estimated from available data

The six systematic reviews explicitly or implicitly used generally different eligibility criteria, resulting in large overlaps in the trials included.169, 189–193. The systematic reviews included a total of 64 trials. The largest systematic review189 included trials up to 1997 and was an update of a previous review191 that reported more analyses. The next largest systematic review190 was one of the more recent systematic reviews (including trials through 2003). The most recent systematic review169 was restricted to trials of people with hypertension. Five more recent trials, not included in any of the systematic reviews were found.120, 194–197 Two of the trials were restricted to normotensive individuals; none included only people with hypertension.

Normotensive individuals

The systematic reviews by Bucher et al. (1996)191 and Allender et al. (1996)192 evaluated trials of normotensive individuals. The range of intervention calcium doses were approximately 400 to 2000 mg/d, with most studies using 1000 to 1500 mg/d. Both found no significant effect of calcium supplementation on blood pressure (net effect on systolic blood pressure of −0.27 and −0.53 mm Hg, respectively, and on diastolic blood pressure of −0.33 and −0.28 mm Hg, respectively). The two additional, more recent primary studies of normotensive participants were consistent with this finding. The TOHP trial compared calcium supplement to placebo in people without hypertension but high normal diastolic blood pressure (80–89 mm Hg) and found a nonsignificant net change in blood pressure of approximately −0.5/+0.35 mm Hg (systolic/diastolic) after 18 months.195 Lijnen 1995 also compared calcium supplement to placebo, but in men who had been put on a low calcium run-in diet, and found a nonsignificant net change in blood pressure of approximately −2/−1 mm Hg after 4 months.197 Both trials had methodological quality C due to inadequate reporting of this outcome or of the background calcium intakes of the participants. Bucher et al. (1996) reported a wide range of study quality; Allender et al. (1996) did not evaluate study quality.

Findings per calcium intake level

Neither systematic review performed subgroup analyses of the normotensive individuals to evaluate a dose (calcium intake) effect. Qualitative examination of the data provided in the systematic review tables and the two additional trials did not indicate any dose effect.

Findings per age and sex

Neither systematic review performed subgroup analyses of the normotensive individuals to evaluate age or sex. The trials in the Allender et al. (1996) systematic review and the two additional trials represented a wide range of ages, though apparently all participants were under age 70 years. Studies were of all men, all women, and both sexes. There were no apparent differences based on age or sex.

Hypertensive individuals

Four systematic reviews evaluated trials of hypertensive individuals (Bucher et al. 1996^191^, Allender et al. 1996^192^, Cappuccio et al. 1989^193^, and Dickinson 2006^198^). Dickinson et al. (2006) included only studies of people with hypertension. The range of supplemental calcium was approximately 400 to 2000 mg/d in most systematic reviews, with most studies using 1000 to 1500 mg/d. The systematic reviews generally found significant effects on systolic blood pressure of about −2 to −4 mm Hg, but no (or small) effects on diastolic blood pressure. The one systematic review that found no effect of calcium supplementation on systolic blood pressure (Cappuccio et al. 1989) was the oldest systematic review (including trials up to only 1988). In addition, the reviewers were highly selective in their eligibility criteria, having excluded trials that did not report various types of baseline data. The one systematic review that found a significant effect of calcium supplementation on diastolic blood pressure (Bucher et al. 1996) meta-analyzed only 6 trial subgroups of people with hypertension, compared to 10 to 16 trials in the other systematic reviews. None of the more recent trials provided analyses in only people with hypertension.

Findings per calcium intake level

Only Dickinson et al. (2006), the systematic review of only trials of people with hypertension, evaluated calcium intake (or dose) as a predictor of effect. They found essentially the same overall effects on systolic and diastolic blood pressures in studies that used less than 1200 mg/d or 1200 to 2000 mg/d of calcium. Qualitative examination of the data provided in the tables of the remaining systematic reviews did not indicate any dose effect.

Findings per age and sex

No systematic review evaluated the association between age or sex and treatment effect in trials of people with hypertension. Overall, the range of ages of participants was about 20 to 75 years. Studies were of all men, all women, and both sexes. There were no apparent differences based on age or sex.

All trials (combined normotensive and hypertensive individuals)

Five systematic reviews (including one which is an update of a second) combined trials of hypertensive, normotensive, or mixed groups of people (Griffith et al. 1999^189^, van Mierlo et al. 2006^190^, Bucher et al. 1996^191^, Allender et al. 1996^192^, and Cappuccio et al. 1989^193^). The range of calcium supplementation was approximately 400 to 2000 mg/d in most systematic reviews, with most studies using 1000 to 1500 mg/d. The systematic reviews generally found a significant effect of calcium supplementation on systolic blood pressure of −0.9 to −1.9 mm Hg (excluding the earliest, highly selective systematic review by Cappuccio et al. (1989)193, as discussed above). The two systematic reviews that included the most studies (Griffith et al. 1999^189^ and van Mierlo et al. 2006^190^) found a significant effect on diastolic blood pressure (−0.8 and −1.0 mm Hg, respectively). The smaller, older systematic reviews found no significant effect (Allender et al. 1996^192^ and Cappuccio et al. 1989^193^). The reason for the difference in conclusions of the systematic reviews may relate to greater statistical power in the more recent meta-analyses or differences in study eligibility criteria. The systematic reviews that reported on study heterogeneity found significant heterogeneity. Three of the systematic reviews reported data on subgroup or regression analyses to explain the heterogeneity. The only factor that explained a significant amount of the heterogeneity was the difference in effect between studies of people with or without hypertension. (The age, sex, and calcium dose analyses are described below.)

Two recent randomized trials included postmenopausal women (over 50 or 55 years) regardless of their blood pressure;120,194 a third trial enrolled pregnant women and evaluated long-term postpartum blood pressures.196 The trials each compared different interventions: calcium citrate 1000 mg versus placebo; dairy product intake (with a mean of 1242 mg/d calcium) versus nondairy product intake (377 mg/d calcium); and calcium carbonate 2000 mg/d versus placebo in women all taking prenatal vitamins that included 400 IU/d vitamin D_2_. The calcium citrate trial was of methodological quality B; the other two trials C. The recent trials found broadly similar conclusions to that of the systematic reviews, with women with greater calcium intake having lower systolic blood pressure (−2.2 to −5.4 mm Hg) and smaller decreases in diastolic blood pressure (−0.7 to −2.2 mm Hg); though none of the effects was statistically significant.

Findings per calcium intake

Three systematic reviews190–192 evaluated calcium dose (or intake) as a source of heterogeneity. None found a significant association. Specifically, van Mierlo et al. (2006) found similar (though smaller) effects in studies of over 1000 mg/d of calcium (SBP/DBP −1.75/−0.56) compared to studies of 1000 mg/d of calcium or less (−2.17/−1.41).

Findings per age and sex

Age and sex were evaluated as potential explanations of heterogeneity in two systematic reviews.190, 192 Neither found that age or sex were significantly associated with the effect of calcium on blood pressure. However, these analyses are subject to ecological fallacy, as they used the mean ages and the percent of study participants who were male as proxies for the effects of calcium intake in people of a particular age or sex. Most studies included participants under age 70 years. Studies were of all men, all women, and both sexes.

Findings by life stage

- 0–6 mo Not reviewed
- 7 mo–2 y Not reviewed
- 3–8 y Not reviewed
- 9–18 y Not reviewed
- 19–50 y The majority of studies are applicable to people within this life stage; though people under approximately 40 years are less well represented. The evidence suggests no significant effect of calcium supplementation on blood pressure in normotensive individuals. In people with hypertension, the evidence suggests that calcium supplementation lowers systolic blood pressure by about −2 to −4 mm Hg, but does not change diastolic blood pressure. The effect appears to be consistent across calcium supplement doses (specifically above or below 1200 mg/d).
- 51–70 y The majority of studies are applicable to people within this life stage. The conclusions are the same as for those in the 19–50 years life stage.
- ≥71 y The evidence is scant for this life stage. Few of the studies appear to have included people over age 70 years.
- Postmenopause Our review of the evidence does not allow for a definitive conclusion for this life stage. None of the systematic reviews evaluated menopausal status as an explanatory variable for heterogeneity.
- Pregnant & lactating women Not reviewed

## Combined Vitamin D and Calcium and Health Outcomes

Women’s Health Initiative (WHI) trial

The WHI trial provided data for numerous health outcomes of interest. For this reason and because of some methodological issues unique to this trial, the study is discussed here. The trial compared combined vitamin D_3_ 400 IU and calcium carbonate 1000 mg daily versus placebo in a 7 year trial in 36,282 postmenopausal women (age 50–79 y). The Tufts EPC, members of the Technical Expert Panel, and reviewers of the draft report debated about the quality of this trial. It was generally agreed that the overall methodological rigor and analyses were of good quality for most outcomes. However, there was not complete consensus on how to regard the fact that the women in both groups of this 7 year trial were allowed to take additional vitamin D supplements up to 600 IU and later 1000 IU per day and calcium supplements up to 1000 mg per day. At baseline, about one-third of women in both supplement and placebo groups were taking vitamin D supplements of at least 400 IU/d and 29 percent were taking at least 500 mg/d of supplemental calcium; by the end of the trial 69 percent of women were taking any additional supplemental calcium. During the 7 years, only about 60 percent of women (in any given year) were taking at least 80 percent of the study pills; at the end of the trial, only 76 percent were still taking any study medications. Regarding the overall quality of the study, arguments were put forward that this was a high quality effectiveness trial (in contrast with a more standardized efficacy trial) and thus had increased relevance to the actual use of supplements, that the crossover of interventions affects the applicability more than the methodological quality, and that the trial should not be downgraded because data reporting was more complete than for most trials. However, it was the consensus among the Tufts EPC that overall, the methodological quality of the trial was B, particularly when the trial is being used to guide decisions about DRI, as opposed to decisions about whether to actively recommend supplementation for an individual woman.

### Combined Vitamin D Calcium and Growth

We reviewed primary studies that evaluated relationships between vitamin D and growth parameters in infants and children.

Synopsis

One C-rated nonrandomized study compared combined vitamin D (1200 IU/d) and calcium (375 mg/d) to no supplementation in women in their third trimester of pregnancy. Infants of women who received supplementation were significantly heavier at birth.

Detailed presentation

(Tables 4 & 6)

Infant 0 – 6 months; 7 months – 2 years; pregnant or lactating women

We identified a study from India that included a nonrandomized comparison between combined vitamin D (1200 IU/d) and calcium (375 mg/d) for the expectant mothers versus no supplementation. The outcome was infant birth weight.41 This study has already been described in the “Vitamin D and growth” section, as it also included a vitamin D only intervention arm. The study included expectant mothers with daily milk intake less than 500 mL and estimated daily vitamin D intake less than 30 IU. It was rated C for methodological quality, because of the lack of randomization and incomplete reporting of analyses. According to the reported analysis, infants of women who received supplementation were significantly heavier at birth by 160 g on average (95 percent CI 0, 320).

Findings by life stage

- 0–6 mo One C-rated nonrandomized study from India compared combined vitamin D (1200 IU/d) and calcium (375 mg/d) to no supplementation in women in their third trimester of pregnancy. Infants of women who received supplementation were significantly heavier at birth by 160 g on average (95 percent CI 0, 320). (See also the Pregnant & lactating women.)
- 7 mo–2 y No identified study covered this life stage.
- 3–8 y No identified study covered this life stage.
- 9–18 y No identified study covered this life stage.
- 19–50 y Not reviewed
- 51–70 y Not reviewed
- ≥71 y Not reviewed
- Postmenopause Not reviewed
- Pregnant & lactating women One C-rated nonrandomized study from India compared combined vitamin D (1200 IU/d) and calcium (375 mg/d) to no supplementation in women in their third trimester of pregnancy. Infants of women who received supplementation were significantly heavier at birth by 160 g on average (95 percent CI 0, 320). (See also the 0–6 mo category.)

### Combined Vitamin D and Calcium and Cardiovascular Disease

Synopsis

No qualified systematic reviews evaluated the association between combined vitamin D and calcium, body stores, or serum concentrations, and cardiovascular events. A variety of cardiovascular events after 7 years were evaluated in the Women’s Health Initiative (WHI) trial of combined daily vitamin D_3_ 400 IU and calcium carbonate 1000 mg versus placebo in 50 to 79 year old women. No statistically significant effect was found with combined vitamin D and calcium supplementation on any cardiovascular outcome. However, near significant associations were found for three outcomes, suggesting increased risk with supplementation for a composite cardiac outcome that included invasive cardiac interventions, invasive cardiac interventions, and transient ischemic attacks. No significant associations were found for cardiovascular death, a composite cardiac outcome (myocardial infarction or cardiac death), coronary heart disease death, myocardial infarction, hospitalization for heart failure, angina, combined stroke or transient ischemic attack, stroke alone, or cerebrovascular death.

Detailed presentation

(Tables 85 & 86)

Table 85 Combined vitamin D and calcium and cardiovascular outcomes: Characteristics of RCTs

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Hsia 2007^199^ LaCroix 2009^200^ WHI US (various) [17309935 19221190] | - Health status; - Mean age (range), y; - Male (%) | Any 62 (50–79) 0 | Ca: 1148 (654) mg/d in treatment group; 1154 (658) in placebo group Low Ca intake (<800 mg/day): 34% | Combined Vit D & Ca supplement vs. Placebo | See page 242

Table 86 Combined vitamin D and calcium and cardiovascular outcomes: Results of RCTs

Author Year Study Name [PMID] | Life Stage | Outcome | 1°/2° | Mean Followup, y | Interventions, Daily Dose | n Event | N Total | Outcome Metric (Comparison) | Result | 95% CI | P Btw | Study Quality
Hsia 2007^199^ LaCroix 2009^200^ WHI [17309935 19221190] | 50–79 y, Women | Cardiovascular death | 2° | 7 | Vit D + Ca | 226 | 18,176 | HR (Suppl/Placebo) | 0.92* | 0.77, 1.10 | NS | B
Hsia 2007^199^ LaCroix 2009^200^ WHI [17309935 19221190] | 50–79 y, Women | Cardiovascular death | 2° | 7 | Placebo | 244 | 18,106 | | | | | B
Hsia 2007^199^ LaCroix 2009^200^ WHI [17309935 19221190] | 50–79 y, Women | Cardiac composite(MI, CHD death, CABG, or PCI) | 2° | 7 | Vit D_3_ 400 IU + Ca carbonate 1000 mg | 920 | 18,176 | HR | 1.08 | 0.99, 1.19 | 0.10 | B
Hsia 2007^199^ LaCroix 2009^200^ WHI [17309935 19221190] | 50–79 y, Women | Cardiac composite(MI, CHD death, CABG, or PCI) | 2° | 7 | Placebo | 841 | 18,106 | | | | | B
Hsia 2007^199^ LaCroix 2009^200^ WHI [17309935 19221190] | 50–79 y, Women | Cardiac composite(MI or CHD death) | 2° | 7 | Vit D + Ca | 499 | 18,176 | HR | 1.04 | 0.92, 1.18 | 0.50 | B
Hsia 2007^199^ LaCroix 2009^200^ WHI [17309935 19221190] | 50–79 y, Women | Cardiac composite(MI or CHD death) | 2° | 7 | Placebo | 475 | 18,106 | | | | | B
Hsia 2007^199^ LaCroix 2009^200^ WHI [17309935 19221190] | 50–79 y, Women | CHD death | 2° | 7 | Vit D + Ca | 130 | 18,176 | HR | 1.01* | 0.79, 1.29 | 0.92 | B
Hsia 2007^199^ LaCroix 2009^200^ WHI [17309935 19221190] | 50–79 y, Women | CHD death | 2° | 7 | Placebo | 128 | 18,106 | | | | | B
Hsia 2007^199^ LaCroix 2009^200^ WHI [17309935 19221190] | 50–79 y, Women | MI | 2° | 7 | Vit D + Ca | 411 | 18,176 | HR | 1.05 | 0.91, 1.20 | 0.52 | B
Hsia 2007^199^ LaCroix 2009^200^ WHI [17309935 19221190] | 50–79 y, Women | MI | 2° | 7 | Placebo | 390 | 18,106 | | | | | B
Hsia 2007^199^ LaCroix 2009^200^ WHI [17309935 19221190] | 50–79 y, Women | CABG or PCI | 2° | 7 | Vit D + Ca | 674 | 18,176 | HR | 1.09 | 0.98, 1.22 | 0.12 | B
Hsia 2007^199^ LaCroix 2009^200^ WHI [17309935 19221190] | 50–79 y, Women | CABG or PCI | 2° | 7 | Placebo | 607 | 18,106 | | | | | B
Hsia 2007^199^ LaCroix 2009^200^ WHI [17309935 19221190] | 50–79 y, Women | Hospitalized for heart failure | 2° | 7 | Vit D + Ca | 394 | 18,176 | HR | 0.95 | 0.83, 1.10 | 0.50 | B
Hsia 2007^199^ LaCroix 2009^200^ WHI [17309935 19221190] | 50–79 y, Women | Hospitalized for heart failure | 2° | 7 | Placebo | 407 | 18,106 | | | | | B
Hsia 2007^199^ LaCroix 2009^200^ WHI [17309935 19221190] | 50–79 y, Women | Angina | 2° | 7 | Vit D + Ca | 404 | 18,176 | HR | 1.08 | 0.94, 1.24 | 0.30 | B
Hsia 2007^199^ LaCroix 2009^200^ WHI [17309935 19221190] | 50–79 y, Women | Angina | 2° | 7 | Placebo | 377 | 18,106 | | | | | B
Hsia 2007^199^ LaCroix 2009^200^ WHI [17309935 19221190] | 50–79 y, Women | Cerebrovascular composite(Stroke or TIA) | 2° | 7 | Vit D + Ca | 563 | 18,176 | HR | 1.02 | 0.91, 1.15 | 0.75 | B
Hsia 2007^199^ LaCroix 2009^200^ WHI [17309935 19221190] | 50–79 y, Women | Cerebrovascular composite(Stroke or TIA) | 2° | 7 | Placebo | 547 | 18,106 | | | | | B
Hsia 2007^199^ LaCroix 2009^200^ WHI [17309935 19221190] | 50–79 y, Women | Stroke | 2° | 7 | Vit D + Ca | 362 | 18,176 | HR | 0.95 | 0.82, 1.10 | 0.51 | B
Hsia 2007^199^ LaCroix 2009^200^ WHI [17309935 19221190] | 50–79 y, Women | Stroke | 2° | 7 | Placebo | 377 | 18,106 | | | | | B
Hsia 2007^199^ LaCroix 2009^200^ WHI [17309935 19221190] | 50–79 y, Women | TIA | 2° | 7 | Vit D + Ca | 213 | 18,176 | HR | 1.16 | 0.95, 1.42 | 0.13 | B
Hsia 2007^199^ LaCroix 2009^200^ WHI [17309935 19221190] | 50–79 y, Women | TIA | 2° | 7 | Placebo | 182 | 18,106 | | | | | B
Hsia 2007^199^ LaCroix 2009^200^ WHI [17309935 19221190] | 50–79 y, Women | Cerebrovascular death | 2° | 7 | Vit D + Ca | 213 | 18,176 | HR | 0.89* | 0.62, 1.29 | NS | B
Hsia 2007^199^ LaCroix 2009^200^ WHI [17309935 19221190] | 50–79 y, Women | Cerebrovascular death | 2° | 7 | Placebo | 182 | 18,106 | | | | | B

In the WHI trial, discussed above, the evaluated cardiovascular outcomes were all prespecified secondary outcomes.199,200 On average, the women had normal blood pressure. There were no significant effects of the supplementation on any of the outcomes, though three of the outcomes did approach statistical significance suggesting increased events with supplementation: composite cardiac events (HR = 1.08 [95 percent CI 0.99, 1.19]), coronary artery bypass grafting or percutaneous coronary interventions (HR=1.09 [95 percent CI 0.98, 1.22]), and transient ischemic attacks (HR=1.16 [95 percent CI 0.95, 1.42]). The authors, however, concluded that calcium and vitamin D supplementation neither increased nor decreased coronary or cerebrovascular risk in generally healthy postmenopausal women. The outcomes cardiac death and stroke were evaluated by age decade. No interaction was found with age (no significant difference across age groups). A similar analysis based on total calcium intake (dietary plus supplemental) also found no interaction.

Findings per intake level

No conclusions are possible about a dose effect from this single study, especially since the women were allowed to take additional concurrent calcium and vitamin D supplements. However, no interaction was found with total reported calcium intake.

Findings by age and sex

The study investigated postmenopausal women 50 to 79 years old. No interaction of effects with decade of age was found.

Findings by life stage

- 0–6 mo Not reviewed
- 7 mo–2 y Not reviewed
- 3–8 y Not reviewed
- 9–18 y Not reviewed
- 19–50 y No data available
- 51–70 y One large trial that included women mostly within this life stage (WHI) found no significant effect of combined vitamin D_3_ (400 IU) and calcium carbonate (1000 mg) on cardiovascular outcomes after 7 years.
- ≥71 y Inadequate available data.
- Postmenopause All women in the WHI trial were postmenopausal. See 51–71 y life stage.
- Pregnant & lactating women Not reviewed

### Combined Vitamin D and Calcium and Body Weight

We searched for systematic reviews and primary studies that evaluated associations between combined vitamin D and calcium and incidence of overweight or obesity; no such studies were found. For the outcome weight change (in kilograms or body mass index units), we included only randomized controlled trials. The EPC and the TEP agreed that the limited resources would not be expended on reviewing observational studies for the surrogate outcome body weight (where overweight or obesity are considered to be the clinical outcomes). We included only studies of adults. Studies of weight gain in children are included in the “Growth” section.

Synopsis

No qualified systematic reviews evaluated the association between combined vitamin D and calcium, body stores, or serum concentrations, and body weight in adults. One RCT each tested the effect of combined vitamin D and calcium in the setting of either an isocaloric diet or an energy restricted diet. Both used vitamin D_2_ 400 IU/d and calcium carbonate (one 1000 mg/d, one 1200 mg/d) and were restricted to women. In the WHI trial of postmenopausal women on an isocaloric diet after 7 years, there was a statistically significant 0.1 kg smaller weight gain in those assigned to the supplement. The effect was statistically similar across age groups. In a Quebec study of 63 overweight premenopausal women, the apparent effect of supplementation in the setting of an energy restricted diet was greater than the WHI trial (net change −1.0 kg), but this was not a significant difference between the supplement and placebo groups.

Detailed presentation

(Tables 87 & 88)

Table 87 Combined vitamin D and calcium and weight: Characteristics of RCTs

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Caan 2007^201^ WHI US (various) [17502530] | - Health status; - Mean age (range), y; - Male (%) | All, post- menopause 62 (50–79) 0 | Ca: 1148 (654) mg/d in treatment group; 1154 (658) in placebo group | Vit D & Ca carbonate vs. Placebo | See page 242 | Factorial design with HT vs. Placebo
Major 2007^202^ Quebec City, Canada (47°N) [17209177] | - Health status; - Mean age (range/SD), y; - Male (%) | Overweight, healthy, pre- menopause 43 (5.5) 0 | Ca 704 mg/d | Vit D + Ca carbonate vs Placebo. | nd | Energy restriction

Table 88 Combined vitamin D and calcium and weight: Results of RCTs

Author Year Study Name [PMID] | Age Range, Sex(Subgp) | Outcome | 1°/2° | Mean Followup | Interventions, Daily Dose | No. Analyzed | Unit | Baseline | Change | Change95% CI | Net Diff | Net Diff95% CI | P Btw | Study Quality
Isocaloric Diet
Caan 2007^201^ WHI [17502530] | 50–79 y, Women | Weight | 2° | 7 y | Vit D_2_ 400 IU + Ca carbonate1000 mg | 18,129 | kg | 76.0 | nd | nd | −0.13 | −0.21, −0.05 | .001^A^ | B
Caan 2007^201^ WHI [17502530] | 50–79 y, Women | Weight | 2° | 7 y | Placebo | 18,055 | | 75.9 | nd | nd | | | | B
Caan 2007^201^ WHI [17502530] | (50–54 y) | | | | Vit D_3_ + Ca | 2592 | kg | nd | nd | | −0.24 | −0.45, −0.03 | <0.05^B^ | B
Caan 2007^201^ WHI [17502530] | (50–54 y) | | | | Placebo | 2561 | | nd | nd | | | | | B
Caan 2007^201^ WHI [17502530] | (55–59 y) | | | | Vit D_3_ + Ca | 4134 | kg | nd | nd | | −0.08 | −0.24, +0.09 | NS | B
Caan 2007^201^ WHI [17502530] | (55–59 y) | | | | Placebo | 4135 | | nd | nd | | | | | B
Caan 2007^201^ WHI [17502530] | (60–69 y) | | | | Vit D_3_ + Ca | 8276 | kg | nd | nd | | −0.15 | −0.27, −0.03 | <0.05 | B
Caan 2007^201^ WHI [17502530] | (60–69 y) | | | | Placebo | 8243 | | nd | nd | | | | | B
Caan 2007^201^ WHI [17502530] | (70–79 y) | | | | Vit D_3_ + Ca | 3174 | kg | nd | nd | | −0.10 | −0.27, +0.09 | NS | B
Caan 2007^201^ WHI [17502530] | (70–79 y) | | | | Placebo | 2561 | | nd | nd | | | | | B
Caan 2007^201^ WHI [17502530] | (White) | | | | Vit D_3_ + Ca | 15,047 | kg | nd | nd | | −0.13 | −0.22, −0.04 | <0.05^C^ | B
Caan 2007^201^ WHI [17502530] | (White) | | | | Placebo | 15,106 | | nd | nd | | | | | B
Caan 2007^201^ WHI [17502530] | (Black) | | | | Vit D3 + Ca | 1682 | kg | nd | nd | | −0.32 | −0.59, −0.06 | <0.05 | B
Caan 2007^201^ WHI [17502530] | (Black) | | | | Placebo | 1635 | | nd | nd | | | | | B
Caan 2007^201^ WHI [17502530] | (Hispanic) | | | | Vit D_3_ + Ca | 789 | kg | nd | nd | | −0.08 | −0.48, +0.32 | NS | B
Caan 2007^201^ WHI [17502530] | (Hispanic) | | | | Placebo | 718 | | nd | nd | | | | | B
Caan 2007^201^ WHI [17502530] | (Asian/Pacific Islander) | | | | Vit D_3_ + Ca | 369 | kg | nd | nd | | +0.19 | −0.37, +0.75 | NS | B
Caan 2007^201^ WHI [17502530] | (Asian/Pacific Islander) | | | | Placebo | 353 | | nd | nd | | | | | B
Energy Restricted Diet
Major 2007^202^ Quebec City, Canada [17209177] | 43 (SD) | Weight | 2° | 15 wk | Vit D_2_ 400 IU + Ca carbonate1200 mg | 30 | kg | 81.5 | −4.0 | ++−9.0 | −1.0 | −2.31. +0.31 | 0.19 | C
Major 2007^202^ Quebec City, Canada [17209177] | 43 (SD) | Weight | 2° | 15 wk | Placebo | 33 | | 83.6 | −3.0 | +−11.7 | | | | C

A In addition, subgroup analyses by baseline BMI and baseline dietary calcium intake are reported.

B No statistically significant interaction with age.

C No statistically significant interaction with ethnicity.

Isocaloric diet

The WHI trial was analyzed for the effect of daily combined vitamin D_2_ 400 IU and calcium carbonate 1000 mg on weight.201 The trial included about 36,000 postmenopausal women aged 50 to 79 years. The methodological quality of the study was B. At 7 year followup, the net change in body weight (supplemented minus control) was −0.13 kg (95 percent CI −0.21, −0.05; less weight gained in supplement group). This was of questionable clinical significance, but was statistically significant. The investigators performed numerous subgroup analyses including those based on age. There were no substantive or statistically significant differences among the evaluated age subgroups.

Energy restricted diet

A trial performed in Quebec City analyzed 63 premenopausal overweight or obese women (mean age 43) comparing daily vitamin D_2_ 400 IU and calcium carbonate 1200 mg versus placebo.202 Women in both study groups were placed on a weight-loss intervention which consisted of a 700 Kcal/day decrease in energy intake for 15 weeks; the women met biweekly with a nutritionist. The trial was rated methodological quality C due to a high drop out rate (25 percent) and poor description of the methodology. Women in both study groups on average lost weight, with those in the supplement group losing 1.0 kg more (4 vs. 3 kg). However, this effect was not statistically significant (P=0.19).

Findings per vitamin D and calcium dose

No conclusion could be reached about a possible effect of vitamin D and calcium dose.

Findings per age and sex

The trials included only women. The effect of supplementation on postmenopausal women not on an energy restricted diet was of questionable clinical significance after 7 years. The effect of supplementation for 15 weeks on overweight and obese premenopausal women (in an approximate age range of 32 to 54 years) on an energy restricted diet was relatively large (−4 vs. −3 kg), but this difference between the supplemented and control groups was not statistically significant.

Findings by life stage

- 0–6 mo Not reviewed
- 7 mo–2 y Not reviewed
- 3–8 y Not reviewed
- 9–18 y Not reviewed
- 19–50 y A single trial of women on an energy restricted diet found a nonsignificant difference in weight loss between that those assigned to vitamin D 300 IU and calcium 1200 mg supplementation for 15 weeks.
- 51–70 y The WHI trial found no clinically significant effect on weight of vitamin D 300 IU and calcium 1000 mg after 7 years.
- ≥71 y The subgroup of women in the WHI trial in this life stage had a similar net weight change as all the study participants as a whole, but the effect was not statistically significant.
- Posmenopause All the women in the WHI trial were postmenopausal.
- Pregnant & lactating women Not reviewed

### Combined Vitamin D and Calcium and Cancer

#### Cancer from all causes and total cancer mortality

Synopsis

No qualified systematic reviews evaluated the association between combined vitamin D and calcium, body stores, or serum concentrations, and total cancer incidence or mortality. Two RCTs reported different effects of combined vitamin D_3_ and calcium supplementation on the risk of total cancer. The WHI showed no effects,71 while the trial conducted in Nebraska (latitude 41°N) reported significant reduction of risk of total cancer.52 However, both vitamin D doses and baseline vitamin D status were substantially different between these two RCTs. Therefore, the effects from these two RCTs were not comparable.

Detailed presentation

(Tables 89 & 90)

Table 89 Combined vitamin D and calcium and total cancer incidence: Characteristics of RCTs

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Wactawski-Wende 2006^71^ WHI US (various) [16481636] | - Health status; - Mean age (range/SD), y | Post-menopausal women nd (50–79) | Ca intake (mg/d): <800, 34%; 800-200, 26%; ≥1200, 40% Median 25(OH)D: 42 nmol/L | Vit D_3_ 400 IU/d + Ca 1000 mg/d vs. Placebo | See page 242
Lappe 2007^52^ Nebraska, US (41°N) [17556697] | - Health status; - Mean age (range/SD), y | Mentally and physically fit; post-menopause 67 (7.3) | 25(OH)D: 71.8 nmol/L | Vit D_3_ 1000 IU/d + Ca (citrate 1400 mg/d or carbonate 1500 mg/d) vs. Ca (citrate 1400 mg/d or carbonate 1500 mg/d) vs. placebo | nd

Table 90 Combined vitamin D and calcium and total cancer incidence: Results of RCTs

Author Year Study Name [PMID] | Life Stage | Outcome | 1°/2° | Followup, year | Interventions, Daily Dose | n Event | N Total | Outcome Metric (Comparison) | Result | 95% CI | P Btw | Study Quality
Wactawski-Wende 2006^71^ WHI [16481636] | Post- menopausal women | Incident cancer (all causes) | 2° | 7 | Vit D_3_ 400 IU + Ca carbonate 1000 mg | 1634 | 18176 | Adjusted HR (Vit D+Ca)/placebo | 0.98 | 0.91, 1.05 | 0.53 | B
Wactawski-Wende 2006^71^ WHI [16481636] | Post- menopausal women | Incident cancer (all causes) | 2° | 7 | Placebo | 1655 | 18106 | | | | | B
Wactawski-Wende 2006^71^ WHI [16481636] | Post- menopausal women | Total cancer mortality | 2° | 7 | Vit D_3_ 400 IU + Ca carbonate 1000 mg | 344 | 18176 | Adjusted HR (Vit D+Ca)/placebo | 0.89 | 0.77, 1.03 | 0.12
Wactawski-Wende 2006^71^ WHI [16481636] | Post- menopausal women | Total cancer mortality | 2° | 7 | Placebo | 382 | 18106
Lappe 2007^52^ [17556697] | Post- menopausal women | Incident cancer (all causes) | 2° | 4 | Vit D_3_ 1000 IU + Ca (citrate 1400 mg or carbonate 1500 mg) | 13 | 446 | RR (Vit D+Ca)/placebo | 0.40 | 0.20, −0.82 | 0.01 | B
Lappe 2007^52^ [17556697] | Post- menopausal women | Incident cancer (all causes) | 2° | 4 | Placebo | 20 | 288 | | | | | B
Lappe 2007^52^ [17556697] | Post- menopausal women | Incident cancer(restrict to subjects who were free of cancer at 1 y intervention) | 2° | 4 | Vit D_3_ 1000 IU + Ca (citrate 1400 mg or carbonate 1500 mg) | 8 | 403 | RR (Vit D+Ca)/placebo | 0.23 | 0.09, −0.60 | <0.005
Lappe 2007^52^ [17556697] | Post- menopausal women | Incident cancer(restrict to subjects who were free of cancer at 1 y intervention) | 2° | 4 | Placebo | 20 | 288

The 7-year WHI trial that enrolled 36,282 postmenopausal women across the US compared a daily supplement of vitamin D_3_ (400 IU) and elemental calcium (1000 mg) with placebo and evaluated incidence of total cancer and total cancer mortality as part of multiple secondary analyses.71 The median serum 25(OH)D level of the study population was 42 nmol/L. The trial did not find significant effect of combined vitamin D_3_ and calcium supplementation on either the risk of total cancer (adjusted HR: 0.98, 95 percent CI 0.91, 1.05) or total cancer mortality (adjusted HR: 0.89, 95 percent CI 0.77, 1.03). The methodological quality of this study was rated B.

A 4-year population based RCT,52 sampled from a 9-county, largely rural area in eastern Nebraska (latitude 41°N), aimed to determine the efficacy of vitamin D_3_ (1000 IU/d) plus calcium (either calcium citrate 1400 mg/d or calcium carbonate 1500 mg/d), or calcium alone (either calcium citrate 1400 mg/d or calcium carbonate 1500 mg/d), compared to placebo in reducing the incidence of fracture. Incidence of cancer was a secondary outcome in this trial. A total of 734 postmenopausal women, aged more than 55 years old, were analyzed for the effect of vitamin D_3_ (1000 IU/d) plus calcium (either calcium citrate 1400 mg/d or calcium carbonate 1500 mg/d). The mean 25(OH)D concentration at baseline was 72 nmol/L. Compared to the placebo group, the relative risk of developing cancer at the end of study was 0.40 (95 percent CI 0.20, 0.82; P=0.013) for the vitamin D_3_ plus calcium group. On the hypothesis that cancers diagnosed early in the study would have been present, although unrecognized at entry, the analyses were restricted to women who were free of cancer at 1 year intervention. The relative risk of developing cancer at the end of study for the vitamin D_3_ plus calcium group changed to 0.23 (95 percent CI 0.09, 0.60; P= 0.005). The methodological quality of this study was rated B.

Findings by life stage

- 0–6 mo No data
- 7 mo–2 y No data
- 3–8 y No data
- 9–18 y No data
- 19–50 y No data
- 51–70 y No data
- ≥71 y No data
- Postmenopause The WHI trial using vitamin D_3_ 400 IU/d plus calcium carbonate 1000 mg/d showed no effects, while the trial in Nebraska using vitamin D_3_ 1000 IU/d plus calcium citrate or carbonate 1500 mg/d showed significant reduction of risk of total cancer.
- Pregnant & lactating women No Data

#### Colorectal cancer

Synopsis

No qualified systematic reviews evaluated the association between combined vitamin D and calcium, body stores, or serum concentrations, and colorectal cancer mortality or incidence. One B quality RCT of postmenopausal women reported no significant association between supplemental vitamin D_3_ and calcium and, colorectal cancer mortality or incidence.

Detailed presentation

(Table 91 & 92)

Table 91 Combined vitamin D with calcium and colorectal cancer: Characteristics of RCTs

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Wactawski-Wende 2006^71^ WHI US (various) [16481636] | - Health status; - Mean age (range), y; - Male (%) | Post-menopausal women nd (50–79) 0 | Total Ca intake (mg/d) (Mean for both groups: 1151) Ca + Vit D arm: 1148; - <800: 34%; - 800-<1200: 26%; - ≥1200: 39%; Placebo arm: 1154; - <800: 33%; - 800-<1200: 26%; - ≥1200: 40%; Total Vit D intake (IU/d) (Mean for both groups: 367) Ca + Vit D arm: nd; - <200: 38%; - 200-<400: 19%; - 400-<600: 23%; - 600: 19%; Placebo arm: nd; - <200: 37%; - 200-<400: 19%; - 400-<600: 24%; - 600: 19% | Ca 1000 mg/d + Vit D_3_ 400 IU/d vs. Placebo | See page 242 | The outcomes were based on self-reported questionnaires. Only colorectal cancers were verified centrally. Colorectal cancer screening was not mandated in the protocol. Lost to followup:; - Ca + Vit D arm: 0.8%; - Placebo arm: 0.8%; Withdrawn:; - Ca + Vit D arm: 1.9%; - Placebo arm: 1.8%

Table 92 Combined vitamin D with calcium and colorectal cancer: Results of RCTs

Author Year Study Name [PMID] | Life Stage | Outcome | 1°/2° | Mean Followup, y | Interventions, Daily Dose | n Event | N Total | Outcome Metric (Comparison) | Result | 95% CI | P Btw | Study Quality
Wactawski-Wende 2006^71^ WHI [16481636] | Post- menopausal women | Colorectal cancer mortality | 2° | 7 | Vit D3 400 IU + Ca carbonate 1000 mg | 34 | 18,176 | HR (Suppl/Placebo) | 0.82 | 0.52, 1.29 | 0.39 | B
Wactawski-Wende 2006^71^ WHI [16481636] | Post- menopausal women | Colorectal cancer mortality | 2° | 7 | Placebo | 41 | 18,106 | | | | | B
Wactawski-Wende 2006^71^ WHI [16481636] | | Colorectal cancer | 2° | | Vit D + Ca | 168 | 18,176 | HR | 1.08 | 0.86, 1.34 | 0.51
Wactawski-Wende 2006^71^ WHI [16481636] | | Colorectal cancer | 2° | | Placebo | 154 | 18,106
Wactawski-Wende 2006^71^ WHI [16481636] | | Colon cancer | 2° | | Vit D + Ca | 128 | 18,176 | HR | 1.00 | 0.78, 1.28 | 0.99
Wactawski-Wende 2006^71^ WHI [16481636] | | Colon cancer | 2° | | Placebo | 126 | 18,106
Wactawski-Wende 2006^71^ WHI [16481636] | | Rectal cancer | 2° | | Vit D + Ca | 44 | 18,176 | HR | 1.46 | 0.92, 2.32 | 0.11
Wactawski-Wende 2006^71^ WHI [16481636] | | Rectal cancer | 2° | | Placebo | 30 | 18,106

The WHI compared daily supplemental vitamin D_3_ (400 IU) and elemental calcium (1000 mg) with placebo in 36,282 postmenopausal women. Colorectal cancer was evaluated as a secondary endpoint.71 The primary endpoint was the prevention of hip fracture. At 7 years vitamin D_3_ and calcium supplementation had no significant effect on colorectal cancer mortality (P=0.39) or incidence (P=0.51). In a subgroup analysis, risks of colon cancer and rectal cancer were also not significantly different between the supplemented and unsupplemented groups (P=0.99 and P=0.11, respectively). This trial was rated B because it did not restrict the participants from taking calcium or vitamin D supplements; they had mean daily total calcium intake of 1151 mg and vitamin D intake of 367 IU at enrollment.

Findings per special populations

The WHI performed 18 subgroup analyses based on baseline participant characteristics including ethnic groups, body mass index, smoking status, and geographic regions according to solar irradiance.71 No significant interactions were found with these baseline characteristics. The same RCT with multifactorial design reported an interaction between estrogen alone or combined estrogen and progestin therapy, and combined vitamin D and calcium supplementation for colorectal cancer risk in a post hoc analysis.203 Among women concurrently assigned to hormone replacement therapies, colorectal cancer incidence was increased in the combined supplemental vitamin D and calcium arm compared to placebo (HR 1.50, 95 percent CI 0.96, 2.33), whereas among those concurrently assigned to placebo in the estrogen trials, colorectal cancer risk was reduced in the vitamin D plus calcium arm compared to placebo (HR 0.71, 95 percent CI 0.46, 1.09) (P for interaction = 0.02).

Findings by life stage

- 0–6 mo Not reviewed
- 7 mo–2 y Not reviewed
- 3–8 y Not reviewed
- 9–18 y Not reviewed
- 19–50 y No data
- 51–70 y One trial that included women mostly within this life stage (WHI) found no significant association between combined vitamin D_3_ (400 IU) and calcium carbonate (1000 mg) and colorectal cancer mortality or incidence.
- 71+ The WHI included some people within this life stage, but no study adequately evaluated this life stage.
- Postmenopause The WHI exclusively focused on postmenopausal women. The study found no association between vitamin D and calcium intake and colorectal cancer mortality or incidence.
- Pregnant & lactating women Not reviewed

#### Colorectal adenoma

Synopsis

No qualified systematic reviews evaluated the association between combined vitamin D and calcium, body stores, or serum concentrations, and incidence of intestinal adenoma. One B quality RCT of postmenopausal women found no significant effect of combined vitamin D_3_ and calcium supplements on the incidence of colorectal adenoma. Another B quality post hoc subgroup analysis of a secondary prevention trial of adenomatous adenoma reported that calcium supplemented patients with higher baseline 25(OH)D concentrations had significantly lower risk of relapse compared to placebo (interaction P = 0.01 between subgroups). In contrast, no significant difference in relapse rates was found in calcium supplemented patients with lower baseline 25(OH)D concentrations compared to placebo.

Detailed presentation

(Tables 91 & 92)

The WHI compared a daily supplement of vitamin D_3_ (400 IU) and elemental calcium (1000 mg) with placebo and evaluated incidence of self-reported colorectal adenoma as part of multiple secondary analyses.71 At 7 years, the incidence of adenoma was not significantly different between the supplement and placebo groups (p=0.71). All the adenoma cases were based on self-reported data, not verified by medical record review or histopathology report.

A post hoc subgroup analysis of the CPP trial of secondary adenoma prevention on the basis of calcium supplementation (1200 mg of elemental calcium) evaluated the risk of colorectal adenoma stratified by baseline 25(OH)D concentrations.204 The primary endpoint of the original trial was the risk of recurrent adenoma. After 4 years, in the subgroup with 25(OH)D concentrations greater than 72.6 nmol/L at baseline, subjects who received supplemental calcium had a significantly lower incidence of recurrent adenoma compared to placebo (HR=0.71 [95 percent CI 0.57,0.89] versus HR=1.05 [95 percent CI 0.85, 1.29]; interaction P=0.01). In the subgroup with 25(OH)D concentrations lower than 72.6 nmol/L, the risk of recurrence was not significantly different between supplemental calcium and placebo. No subgroup data were available regarding sex, separate life stages, or other special populations (e.g., obese, smokers, ethnic groups, or users of contraceptives).

Findings by life stage

- 0–6 mo Not reviewed
- 7 mo–2 y Not reviewed
- 3–8 y Not reviewed
- 9–18 y Not reviewed
- 19–50 y The CPP included some people within this life stage, but no study adequately evaluated this life stage.
- 51–70 y The analysis of the CPP with a mean age of 61 years included participants mostly within this life stage. The study found a significant association between supplemental calcium and reduced risk of colorectal adenoma in a subgroup with 25(OH)D concentrations higher than 72.6 nmol/L.
- 71+ The CPP included some people within this life stage, but no study adequately evaluated this life stage.
- Postmenopause The WHI found no association between combined vitamin D_3_ and calcium supplements and the incidence of colorectal adenoma.
- Pregnant & lactating women Not reviewed

#### Breast cancer

Synopsis

No qualified systematic reviews evaluated the association between vitamin D and calcium intake, body stores, or serum concentrations, and breast cancer. Breast cancer incidence and breast cancer related mortality after 7 years were evaluated in the Women’s Health Initiative (WHI) trial of combined daily vitamin D_3_ 400 IU and calcium carbonate 1000 mg versus placebo in 50 to 79 year old women without a prior history of breast cancer.205 No statistically significant effect was found with combined vitamin D and calcium supplementation on incident breast cancer outcome. No significant associations were found for breast cancer related mortality.

Detailed presentation

(Tables 93 & 94)

Table 93 Combined vitamin D and calcium and breast cancer outcomes: Characteristics of RCTs

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Chebowski 2008^205^ WHI US (various) [19001601] | - Health status; - Mean age (range), y; - Male (%) | No breast cancer 50–79 0 | Baseline Ca supplementation: Vit D & Ca arm <800: 34.3% 800-<1200: 26.5% ≥1200: 39.3% Placebo arm <800: 33.8% 800-<1200: 26.2% ≥1200: 40.0% Baseline Vit D supplementation: Vit D & Ca arm Yes: 47.1% No: 52.9% Placebo arm Yes 47. 6% No 52.4% | Combined Vit D & Ca supplement vs. Placebo | See page 242 | Intervention and placebo groups were allowed to take additional concurrent calcium and vitamin D supplements.

Table 94 Combined vitamin D and calcium and breast cancer outcomes: Results of RCTs

Author Year Study Name [PMID] | Life Stage | Outcome | 1°/2° | Mean Followup, y | Interventions, Daily Dose | n Event | N Total | Outcome Metric (Comparison) | Result | 95% CI | P Btw | Study Quality
Chebowski 2008^205^ WHI [19001601] | 50–79 y, Women | Breast cancer incidence | 2° | 7 | Vit D_3_ 400 IU + Ca carbonate 1000 mg | 668 | 18176 | HR (Suppl/Placebo) | 0.96 | 0.86, 1.07 | NS | B
Chebowski 2008^205^ WHI [19001601] | 50–79 y, Women | Breast cancer incidence | 2° | 7 | Placebo | 693 | 18106 | | | | | B
Chebowski 2008^205^ WHI [19001601] | 50–79 y, Women | Death from breast cancer | 2° | 7 | Vit D_3_ 400 IU + Ca carbonate 1000 mg | 23 | 18176 | HR | 0.99 | 0.55, 1.76 | NS | B
Chebowski 2008^205^ WHI [19001601] | 50–79 y, Women | Death from breast cancer | 2° | 7 | Placebo | 23 | 18106 | | | | | B
Chebowski 2008^205^ WHI [19001601] | 50–79 y, Women | Invasive breast cancer– subgroup >67.6 baseline 25(OH)D | 2° | 7 | Vit D_3_ 400 IU + Ca carbonate 1000 mg | 86 | 195 | Adj OR | 0.89 | 0.58, 1.36 | NS
Chebowski 2008^205^ WHI [19001601] | 50–79 y, Women | Invasive breast cancer– subgroup >67.6 baseline 25(OH)D | 2° | 7 | Placebo | 76 | 185
Chebowski 2008^205^ WHI [19001601] | 50–79 y, Women | Invasive breast cancer– subgroup 55.4-<67.6 baseline 25(OH)D | 2° | 7 | Vit D_3_ + Ca | 95 | 171 | Adj OR | 1.25 | 0.83, 1.90 | NS
Chebowski 2008^205^ WHI [19001601] | 50–79 y, Women | Invasive breast cancer– subgroup 55.4-<67.6 baseline 25(OH)D | 2° | 7 | Placebo | 86 | 171
Chebowski 2008^205^ WHI [19001601] | 50–79 y, Women | Invasive breast cancer– subgroup 43.9- <55.4 baseline 25(OH)D | 2° | 7 | Vit D_3_+ Ca | 102 | 176 | Adj OR | 1.07 | 0.70, 1.62 | NS
Chebowski 2008^205^ WHI [19001601] | 50–79 y, Women | Invasive breast cancer– subgroup 43.9- <55.4 baseline 25(OH)D | 2° | 7 | Placebo | 92 | 195
Chebowski 2008^205^ WHI [19001601] | 50–79 y, Women | Invasive breast cancer– subgroup 32.4-<43.9 baseline 25(OH)D | 2° | 7 | Vit D_3_+ Ca | 71 | 185 | Adj OR | 0.69 | 0.45, 1.06 | NS
Chebowski 2008^205^ WHI [19001601] | 50–79 y, Women | Invasive breast cancer– subgroup 32.4-<43.9 baseline 25(OH)D | 2° | 7 | Placebo | 102 | 171
Chebowski 2008^205^ WHI [19001601] | 50–79 y, Women | Invasive breast cancer– subgroup <32.4 baseline 25(OH)D | 2° | 7 | Vit D_3_ + Ca | 94 | 171 | Adj OR | 0.91 | 0.60, 1.39 | NS
Chebowski 2008^205^ WHI [19001601] | 50–79 y, Women | Invasive breast cancer– subgroup <32.4 baseline 25(OH)D | 2° | 7 | Placebo | 91 | 176

In the WHI trial, the evaluated breast cancer incidence and breast cancer related mortality outcomes were secondary outcomes.205 There were no significant effects of combined vitamin D and calcium supplementation on both outcomes. The authors concluded that invasive breast cancer incidence was similar in the two groups of healthy postmenopausal women: calcium and vitamin D supplementation and placebo groups. The relationship of 25(OH)D serum concentrations and the risk of breast cancer was examined in a nested case-control design. The study found no relationship between total vitamin D intake and 25(OH)D serum concentrations with the risk of breast cancer.

Findings per intake level

No conclusions are possible regarding a dose effect from this single study, especially since the women in the intervention and placebo groups were allowed to take additional concurrent calcium and vitamin D supplements.

Findings by age and sex

The study investigated postmenopausal women 50 to 79 years old.

Findings by life stage

- 0–6 mo Not reviewed
- 7 mo–2 y Not reviewed
- 3–8 y Not reviewed
- 9–18 y Not reviewed
- 19–50 y No data available
- 51–70 y The WHI trial that included women mostly within this life stage found no significant effect of combined vitamin D_3_ (400 IU) and calcium carbonate (1000 mg) on incident breast cancer and mortality from breast cancer after 7 years.
- ≥71 y Inadequate available data.
- Postmenopause All women in the WHI trial were postmenopausal.
- Pregnant & lactating women Not reviewed

### Combined Vitamin D and Calcium and Pregnancy-related Outcomes

#### Preeclampsia

Synopsis

Based on data from a single RCT, there is no significant effect of combined vitamin D and calcium supplementation on the prevention of preeclampsia.

Detailed presentation

(Tables 95 & 96.)

Table 95 Combined vitamin D and calcium and preeclampsia: Characteristics of RCTs

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Marya 1987^206^ India (29°N) [3623260] | - Health status; - Age range, y | Any 20–35 | Ca: 500 mg/d in in diet; Vit D: ~40 IU/d (unclear how it was quantified) | Combined Vit D (1200 IU/d) & Ca (375 mg/d) supplement vs. no supplement | nd

Table 96 Combined vitamin D and calcium and preeclampsia: Results of RCTs

Author Year Study Name Location (Latitude) [PMID] | Life Stage | Outcome | 1°/2° | Mean Followup, y | Interventions, Daily Dose | n Event | N Total | Outcome Metric (Comparison) | Result | 95% CI | P Btw | Study Quality
Marya 1987^206^ India (29°N) [3623260] | Pregnancy | Toxemia (preeclampsia) | 1° | ND | Vit D (1200 IU) & calcium (375 mg) | 12 | 200 | RR (combined Vit D & Ca vs. nothing) | 0.67 | 0.33, 1.35 | 0.26 | C
Marya 1987^206^ India (29°N) [3623260] | Pregnancy | Toxemia (preeclampsia) | 1° | ND | No supplement | 18 | 200 | RR (combined Vit D & Ca vs. nothing) | | | 0.26 | C

One RCT from India used a combination of vitamin D (1200 IU/d) and calcium (375 mg/d) for the prevention of preeclampsia.206 Table 85 describes the characteristics of the trial. The trial found no significant difference between the compared arms (Table 86). Note that this RCT was excluded from the meta-analysis of trials for preeclampsia in the calcium section.

Findings by life stage

- 0–6 mo No data
- 7 mo–2 y Not applicable
- 3–8 y Not applicable
- 9–18 y Not applicable
- 19–50 y [see pregnant and lactating women]
- 51–70 y Not applicable
- 71+ Not applicable
- Postmenopause Not applicable
- Pregnant & lactating women Based on data from a single RCT, there is no significant effect of combined vitamin D (1200 IU/d) and calcium (375 mg/d) supplementation on the prevention of preeclampsia.

#### Other pregnancy-related outcomes

Synopsis

We did not identify any eligible studies on the relationship of vitamin D with or without calcium and high blood pressure, preterm birth, or small for gestational age infant.

### Combined Vitamin D and Calcium and Clinical Outcomes of Bone Health

#### Rickets, fractures, falls, or performance measures

For bone health outcomes (e.g., bone mineral density, fracture, fall or muscle strength), we relied on a recent comprehensive systematic review performed by the Ottawa EPC (Table 34).6 Because the Ottawa’s EPC report did not have separate analyses for the effect of vitamin D supplementation alone, the results for the effect of vitamin D alone or in combination with calcium supplementation are presented in this section.

The Ottawa EPC report was updated with literature published between January 2006 and April 2009, selected according to our eligibility criteria. Only RCTs qualified for inclusion.

Synopsis

The Ottawa EPC report concluded that supplementation with vitamin D (most studies used D_3_) plus calcium is effective in reducing fractures in institutionalized populations, but there is inconsistent evidence that supplemental vitamin D reduces falls in postmenopausal women and older men.

Our update search did not identify new RCT examining the combined effect of vitamin D plus calcium supplementation on rickets, fractures, or falls in postmenopausal women and older men. One study published after the Ottawa EPC report analyzed the performance measure outcomes in a small sample of postmenopausal women from WHI trial showed generally no differences in performance measures between vitamin D (400 IU/d) plus calcium (1000 mg/d) supplementation or placebo groups after 5 years of followup.207 One RCT of premenopausal women, aged 17 to 35 years old, showed that 800 IU/d of vitamin D in combination with 2000 mg/d of calcium supplementation can reduce the risk of stress fracture from military training compared to placebo.208

Detailed presentation

(Table 34, 97, 98 & 99)

Table 97 Combined vitamin D and calcium and bone health: Characteristics of RCTs published after the Ottawa EPC report

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Lappe 2008^208^ Great Lakes, IL, US (41°N) [18433305] | - Health status; - Mean age (range), y; - Male (%) | Assumed healthy (Navy recruits) 19 (17–35) 0 | Mean dairy servings/wk = 6 (ranged 1–26) | Vit D 800 IU/d + Ca 2000 mg/d vs. Placebo | Monitor pill taking: project staff observed the galley food lines, visited recruits in their quarters, and conducted an exit interview.
Brunner 2008^207^ WHI US (various) [18755319] | - Health status; - Mean age (range), y; - Male (%) | nd (for the sub sample from WHI trial) 50–79 0 | nd | Vit D 400 IU/d + Ca 1000 mg/d vs. Placebo | nd (however, adherence was assessed at least annually from the weight of remaining pills along with a structured interview in WHI trial) | A sub sample from WHI trial. Post hoc analyses of a RCT.

Table 98 Combined vitamin D and calcium and bone health: Results of RCTs published after the Ottawa EPC report (stress fracture)

Author Year Study Name [PMID] | Life Stage | Outcome | 1°/2° | Mean Followup, mo | Interventions, Daily Dose | n Event | N Total | Outcome Metric (Comparison) | Result | 95% CI | P Btw | Study Quality
Lappe 2008^208^ [18433305] | 17–35 y women | Stress fracture from Navy training (ITT) | 1° | 2 | Vit D 800 IU + Ca 200 mg | 139 | 2626 | RR (Vit D+Ca)/placebo | 0.8 | 0.64, 0.99 | 0.026 | B
Lappe 2008^208^ [18433305] | 17–35 y women | Stress fracture from Navy training (ITT) | 1° | 2 | Placebo | 170 | 2575 | | | | | B
Lappe 2008^208^ [18433305] | | Stress fracture from Navy training (per protocol) | 1° | 2 | Vit D 800 IU + Ca 200 mg | 126 | 1852 | Adjusted OR (Vit D+Ca)/placebo | 0.79 | 0.62, 1.01 | 0.059
Lappe 2008^208^ [18433305] | | Stress fracture from Navy training (per protocol) | 1° | 2 | Placebo | 160 | 1848

Table 99 Combined vitamin D and calcium and bone health: Results of RCTs published after the Ottawa EPC report (performance measures)

Author Year Study Name PMID | Life Stage | Outcome | 1°/2° | Mean Followup, mo | Interventions, Daily Dose | No. Analyzed | Unit | Baseline | Change | Change SD | Net Diff | Net Diff 95% CI | P Btw | Study Quality
Brunner 2008^207^ [18755319] | Post-menopause | Grip strength | 2° | 60 | Vit D 400 IU + Ca carbonate 1000 mg | 1185 | kg | 22.81 | −2.49 | 5.81 | 0.15 | 0.24 | 0.52 | C
Brunner 2008^207^ [18755319] | Post-menopause | Grip strength | 2° | 60 | Placebo | 1162 | | 22.96 | −2.64 | 5.69 | | | | C
Brunner 2008^207^ [18755319] | | Chair stands | 2° | 60 | Vit D 400 IU + Ca carbonate 1000 mg | 1065 | counts | 6.52 | −0.38 | 1.81 | 0.04 | 0.08 | 0.603
Brunner 2008^207^ [18755319] | | Chair stands | 2° | 60 | Placebo | 1053 | | 6.63 | −0.43 | 1.81
Brunner 2008^207^ [18755319] | | Walking time | 2° | 60 | Vit D 400 IU + Ca carbonate 1000 mg | 1160 | seconds | | +0.26 | 6.28 | - 0.54 | 0.26 | 0.030
Brunner 2008^207^ [18755319] | | Walking time | 2° | 60 | Placebo | 1141 | | | +0.81 | 6.43

One RCT of female Navy recruits, aged 17 to 35 years, aimed to determine whether supplementation with vitamin D (800 IU/d) plus calcium (2000 mg/d) can reduce the risk of stress fractures from military training near the Great Lakes (41°N).208 The median dairy intake was <1 serving/day, which provided less than 300 mg of calcium. The combined supplementation significantly reduced the risk of stress fractures by 20 percent compared to placebo. The methodological quality of this study was rated B.

One study analyzed the performance measure outcomes in a sample of 2928 postmenopausal women from the WHI trial who had objective physical function measures.207 The results showed that physical function, measured by grip strength, chair stands, and walking time, had generally declined in postmenopausal women who were assigned to either vitamin D (400 IU/d) plus calcium (1000 mg/d) supplementation or placebo group. However, women who had received vitamin D plus calcium supplementation showed less declines in walking time than those who had received placebo. The methodological quality of this study was rated C because only a small proportion of women from the WHI trial were in the analyses and their baseline characteristics were unclear.

From the Ottawa EPC Report: Fractures - Postmenopausal women and older men

Fifteen RCTs examined the effect of either vitamin D_2_ or D_3_ alone or in combination with calcium on total, nonvertebral and hip fractures in postmenopausal women or older men. Few trials evaluated vertebral fractures. Most trials used vitamin D_3_. There were no trials identified in premenopausal women.

Meta-analysis results from 13 RCTs of vitamin D_2_ or D_3_ with or without calcium showed a nonsignificant reduction in the risk of total fractures that persisted when only trials of higher quality were combined. Most trials used vitamin D_3_. When combining seven RCTs of vitamin D_3_ (400–800 IU) plus calcium, there was a reduction in the risk of total and hip fractures. However, in a subgroup analysis (800 IU vitamin D_3_), this benefit was only evident in trials of institutionalized elderly subjects. One possible explanation for the discrepancy is that the mean serum 25(OH)D concentration achieved in trials of institutionalized participants was higher than in the trials on community dwellers. The combined estimate from trials with higher end-of-study serum 25(OH)D concentrations (>74 nmol/L) was consistent with a significant reduction in the risk of fractures.

In Ottawa EPC report: Falls - Postmenopausal women and older men

Meta-analysis results from 12 RCTs demonstrated a small reduction in the risk of falls with supplemental vitamin D_2_ or D_3_ (oral or injectable) with or without calcium (OR 0.89, 95 percent CI 0.80, 0.99). The individual treatment effects ranged from OR 0.28 (95 percent CI 0.12, 0.67) to 1.16 (95 percent CI 0.70, 1.92). In the two cluster RCTs, one demonstrated a significant reduction in the risk of falls in postmenopausal women taking vitamin D_3_ plus calcium (RR 0.88, 95 percent CI 0.79, 0.98), whereas the other trial did not show a significant reduction in the risk of falls in elderly individuals taking vitamin D_2_ (RR 1.09, 95 percent CI 0.95, 1.25). Meta-analysis of eight RCTs of oral vitamin D_2_/D_3_ supplementation with calcium showed a reduction in the risk of falls, whereas four RCTs of oral vitamin D_3_ alone did not. Subgroup analyses showed a significant reduction in the risk of falls when only trials of postmenopausal women were combined. Sensitivity analyses showed a significant reduction in the risk of falls when combining (1) RCTs that explicitly defined falls and the method of fall ascertainment and (2) those in which the allocation concealment was unclear. However, combining trials by degree of compliance and loss to followup did not.

Findings by life stage

- 0–6 mo Not reviewed
- 7 mo–2 y Not reviewed
- 3–8 y Not reviewed
- 9–18 y Not reviewed
- 19–50 y The Ottawa EPC report concluded that supplementation with vitamin D (most studies used D_3_) plus calcium is effective in reducing the risk of fractures in institutionalized populations, but there is inconsistent evidence that supplemental vitamin D reduces the risk of falls in postmenopausal women and older men. One RCT of female Navy recruit, aged 17 to 35 years old, showed that vitamin D (800 IU/d) in combination of calcium (2000 mg/d) supplementation can reduce the risk of stress fractures from military training compared to placebo.
- 51–70 y No new data since the Ottawa report
- 71+ No new data since the Ottawa report
- Postmenopause One study analyzed the performance measure outcomes in a small sample of postmenopausal women from the WHI trial showed generally no differences in performance measures between vitamin D (400 IU/d) plus calcium (1000 mg/d) supplementation and placebo groups after 5 years of followup.
- Pregnant & lactating women No data

### Combined Vitamin D and Calcium and all-cause Mortality

Synopsis

This synopsis is based on a meta-analysis of RCTs of combined vitamin D and calcium supplementation evaluating mortality. Numerical data were extracted from previous systematic reviews. Most trials used daily regimens; in these trials, vitamin D doses ranged between 300 and 880 IU per day. Most trials combined vitamin D and calcium supplementation; when used, calcium doses ranged between 500 and 1200 mg per day.

Our meta-analysis of 11 RCTs (44,688 participants) suggests no significant relationship between combined supplementation of vitamin D and calcium all-cause mortality (RR=0.93, 95 percent CI 0.86, 1.01; random effects model). There is little evidence for between-study heterogeneity in these analyses. Among 8 RCTs on 44,281 postmenopausal women, the summary random effects RR was 0.93 (95 percent CI 0.86, 1.00), again with little evidence for between-study heterogeneity.

Although the meta-analyses suggest decreased risk for all-cause mortality with combined vitamin D and calcium supplementation, the relationship is not statistically significant in the performed analyses.

Detailed presentation

(Table 37; Figure 22)

Figure 22 Forest plot of trials of combined vitamin D and calcium supplementation and effects on all-cause mortality.

As mentioned in the Methods section, we updated and reanalyzed published meta-analyses of mortality outcomes. We drew our own conclusions based on our analyses. We also comment on the concordance of our conclusions with those of the published meta-analyses.

Relevant published systematic reviews of RCTs (with meta-analyses)

As described in the vitamin D and all-cause mortality section, we identified two potentially eligible systematic reviews,83,84 and selected one as the basis for our reanalysis (Autier 2007).83 Table 37 in the “Vitamin D” section summarizes the findings of the Autier 2007 systematic review.

As detailed below, we identified one additional trial of combined vitamin D and calcium supplementation reporting all-cause mortality.209

Eligible studies published after the systematic reviews

The literature searches in Autier 2007 extended up to November 2006. We identified two additional RCT reports published after November 2006.^71,209^ One publication71 reported on the same trial as another publication210 in the Autier 2007 meta-analysis, and was therefore excluded from our reanalysis. The other RCT (Bjorkman 2008^209^) was included in our meta-analysis.

One three-arm RCT (Bjorkman 2008^209^, n=218) compared no supplementation versus daily supplementation with 400 IU and 1200 IU of vitamin D_3_ and 500 mg of calcium. Mortality was assessed at 6 months. It included people older than 65 years, with chronically impaired mobility and stable general condition. The Bjorkman 2008 RCT was assigned grade “A” for overall reporting quality.

Reanalysis

We excluded 5 of 18 trials in the Autier 2007 meta-analysis: One trial was on patients with congestive heart failure,85 one was published only in abstract form,86 and in the last trial the controls also received supplementation with vitamin D, albeit with a smaller dose,87 and two used injections of vitamin D.88,89 Altogether, 11 RCTs were included in the reanalysis of combined vitamin D and calcium supplementation and all-cause mortality (i.e., 10 out of 18 in the Autier 2007 meta-analysis, and a subsequently published one209).

Among the 12 trials, sample sizes ranged from 55 to 36,282 participants, with 7 studies including more than 500 participants. Followup periods ranged from 6 to 84 months (median 24 months). Vitamin D doses in most trials ranged between 300 and 880 IU per day. One trial used 100,000 IU orally every 4 months. Calcium supplementation doses ranged between 500 to 1200 mg per day.

Overall, a meta-analysis of the 11 RCTs (44,688 participants; Figure 22) found no statistically significant relationship between vitamin D and all-cause mortality (RR=0.93, 95 percent CI 0.86, 1.01). There is little evidence for between-study heterogeneity in these analyses (P=0.58, I^2^=0 percent). Among 8 RCTs on 44,281 postmenopausal women, the summary random effects RR was 0.93 (95 percent CI 0.86, 1.00), again with little evidence for between-study heterogeneity (P=0.46, I^2^=0 percent). There are no RCTs with mean participant age below 50 years. It is unclear whether these findings are directly applicable to other life stages. In addition, in a subgroup analysis among 8 RCTs (n=8109) where the mean participant age was above 70 years, the summary random effects RR=0.98 (95 percent CI 0.84, 1.15), with little evidence for between study heterogeneity (P=0.33, I^2^=13 percent).

Findings by life stage

- 0–6 mo No data
- 7 mo–2 y No data
- 3–8 y No data
- 9–18 y No data
- 19–50 y No data
- 51–70 y Our meta-analysis of 12 RCTs (44,838 participants) suggests no significant relationship between combined supplementation of vitamin D and calcium all-cause mortality (RR=0.94, 95 percent CI 0.87, 1.01; random effects model). There is little evidence for between-study heterogeneity in these analyses.
- 71+ The above are likely applicable here. In addition, in a subgroup analysis among 8 RCTs (n=8109) where the mean participant age was above 70 years, the summary random effects RR=0.98 (95 percent CI 0.84, 1.15), with little evidence for between study heterogeneity.
- Postmenopause Among 8 RCTs on 44,281 postmenopausal women, the summary random effects RR was 0.93 (95 percent CI 0.86, 1.00), again with little evidence for between-study heterogeneity.
- Pregnant & lactating women No data

### Combined Vitamin D and Calcium and Hypertension and Blood Pressure

We reviewed systematic reviews and primary studies that evaluated associations between combined vitamin D and calcium intake and incidence of hypertension or change in blood pressure. For the outcome incidence of hypertension, we included RCTs and other longitudinal studies. For the outcome change in blood pressure, we included only RCTs. We included only studies of adults. Studies of pregnancy-related hypertension and blood pressure control are included in the “Pregnancy-related outcomes” section.

#### Combined vitamin D and calcium and hypertension

Synopsis

No qualified systematic reviews evaluated the association between combined vitamin D and calcium intake, body stores, or serum concentrations and incidence of hypertension. The WHI trial reported an analysis of the risk of developing hypertension among the subset of women without hypertension at baseline. Over 7 years, combined vitamin D and calcium supplementation had no effect on the risk of hypertension.

Detailed presentation

(Tables 100 & 101)

Table 100 Combined vitamin D and calcium and incident hypertension: Characteristics of RCTs

AuthorYear Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Margolis 2008^211^ WHI US (various) [18824662] | - Health status; - Mean age (range), y; - Male (%) | No HTN 62 (50–79) 0 | Ca: 1148 (654) mg/d in treatment group; 1154 (658) in placebo group 52% used Ca supplements 40% had intake 1200 mg/d (based on all subjects, including those with hypertension) | Combined Vit D + Ca supplement vs. Placebo | See page242 | Mean dose of open label supplemental Ca increased by <100 mg/d from 325 mg/d at enrollment; similar in both groups (based on all subjects including those with hypertension)

Table 101 Combined vitamin D and calcium and incident hypertension: Results of RCTs

Author Year Study Name [PMID] | Life Stage [Subgp] | Outcome | 1°/2° | Mean Followup, y | Interventions, Daily Dose | n Event | N Total | Outcome Metric (Comparison) | Result | 95% CI | P Btw | Study Quality
Margolis 2008^211^ WHI [18824662] | 50–79 y Women | HTN | 2° | 7 | Vit D_3_ 400 IU + Ca carbonate 1000 mg | 3377 | ~8578 | HR (Suppl/Placebo) | 1.01 | 0.96, 1.06 | 0.69 | B
Margolis 2008^211^ WHI [18824662] | 50–79 y Women | HTN | 2° | 7 | Placebo | 3315 | ~8544 | | | | | B
Margolis 2008^211^ WHI [18824662] | [25(OH)D <34.4 nmol/L] | | | | Vit D + Ca | 53 | | | 1.52 | 0.89, 2.59 | NS
Margolis 2008^211^ WHI [18824662] | [25(OH)D <34.4 nmol/L] | | | | Placebo | 38
Margolis 2008^211^ WHI [18824662] | [25(OH)D 34.4–47.6 nmol/L] | | | | Vit D + Ca | 39 | | | 1.48 | 0.89, 2.46 | NS
Margolis 2008^211^ WHI [18824662] | [25(OH)D 34.4–47.6 nmol/L] | | | | Placebo | 48
Margolis 2008^211^ WHI [18824662] | [25(OH)D 47.7–64.6 nmol/L] | | | | Vit D + Ca | 45 | | | 1.15 | 0.69, 1.92 | NS
Margolis 2008^211^ WHI [18824662] | [25(OH)D 47.7–64.6 nmol/L] | | | | Placebo | 45
Margolis 2008^211^ WHI [18824662] | [25(OH)D ≥64.7 nmol/] | | | | Vit D + Ca | 48 | | | 0.79 | 0.51, 1.22 | NS
Margolis 2008^211^ WHI [18824662] | [25(OH)D ≥64.7 nmol/] | | | | Placebo | 61

The WHI trial of a combined vitamin D_3_ 400 IU and calcium carbonate 1000 mg supplement daily versus placebo had methodological quality B for the blood pressure outcome. The 36,282 women were postmenopausal (age 50–79 y) with a background calcium intake on average of about 1150 mg/day (from diet and supplements).211 The women were allowed to take additional concurrent calcium and vitamin D supplements. The analysis of incident hypertension was reported briefly in a larger analysis of the blood pressure outcome (see Combined vitamin D and calcium and blood pressure, below). Among 17,122 initially nonhypertensive women, 39 percent either were prescribed medication for hypertension or developed blood pressure above 140/90 mm Hg. The adjusted HR of developing hypertension over 7 years was 1.01 (95 percent CI 0.96, 1.06). Among 377 women with available data, there was a statistically significant trend across subgroups based on serum 25(OH)D concentration such that combined vitamin D and calcium supplementation increased the risk of developing hypertension more in those women with progressively lower baseline 25(OH)D (P<0.01 for trend). Other subgroup analyses based on age, race or ethnicity, weight, or baseline total calcium intake did not find any interactions with the effect of the supplement intervention.

Findings per intake level

This single trial did not analyze different actual intake levels.

Findings by age and sex

This trial found no difference in (lack of) effect by age among postmenopausal women.

Findings by life stage

- 0–6 mo Not reviewed
- 7 mo–2 y Not reviewed
- 3–8 y Not reviewed
- 9–18 y Not reviewed
- 19–50 y No data.
- 51–70 y One large trial that included women mostly within this life stage found no significant effect of combined vitamin D and calcium supplementation.
- ≥71 y The WHI trial included some women within the life stage, but no study adequately evaluated this life stage.
- Postmenopause All women in the WHI trial were postmenopausal. See 51–71 y life stage.
- Pregnant & lactating women Not reviewed

#### Combined vitamin D and calcium and blood pressure

Synopsis

No qualified systematic reviews evaluated the association between vitamin D and calcium intake, body stores, or serum concentrations, and changes in blood pressure. Two RCTs compared combined vitamin D and calcium supplementation with placebo. Both the small trial of a combined vitamin D_3_ 400 IU and calcium carbonate 1200 mg supplement daily and the WHI trial found no significant effect of supplementation on blood pressure after 15 weeks or 6.1 years, respectively. The WHI trial analyzed blood pressure changes in a variety of subgroups, including by age, ethnicity, baseline total calcium intake, and baseline diagnosis of hypertension, but found no significant differences in effect across any subgroup.

Detailed presentation

(Tables 102 & 103)

Table 102 Combined vitamin D and calcium and blood pressure: Characteristics of RCTs

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Margolis 2008^211^ WHI US (various) [18824662] | - Health status; - Mean age (range), y; - Male (%) | Any 62 (50–79) 0 | Ca: 1148 (654) mg/d in treatment group; 1154 (658) in placebo group 52% used Ca supplements 40% had intake ≥1200 mg/d | Combined Vit D + Ca supplement vs. Placebo | See page 242 | Mean dose of open label supplemental Ca increased by <100 mg/d from 325 mg/d at enrollment; similar in both groups
Major 2007^202^ Quebec City, Canada (47°N) [17209177] | - Health status; - Mean age (SD), y; - Male (%) | Healthy Overweight, low Ca intake 43 (5.5) 0 | Ca: ~704 mg/d; all<800 mg/d | Combined Vit D + Ca supplement vs. Placebo | nd

Table 103 Combined vitamin D and calcium and blood pressure: Results of RCTs

Author Year Study Name [PMID] | Age Range, Sex | Outcome | 1°/2° | Mean Followup | Interventions Daily Dose, | No. Analyzed | Unit | Baseline | Change | Change 95% CI | Net Diff | Net Diff 95% CI | P Btw | Study Quality
SYSTOLIC BLOOD PRESSURE
Margolis 2008^211^ WHI [18824662 | 50–79, Women | SBP | 2° | 6.1 y | Vit D_3_ 400 IU + Ca carbonate 1000 mg | 18,176 | mm Hg | 127^A^ | +1.1%^A^ | 0.9, 1.3 | +0.22 | −0.05, +0.49 | 0.11 | B
Margolis 2008^211^ WHI [18824662 | 50–79, Women | SBP | 2° | 6.1 y | Placebo | 18,106 | | 128^A^ | +0.7%^A^ | 0.5, 0.9 | | | | B
Major 2007^202^ Quebec City [17209177] | 43 (5.5), Women | SBP | 2° | 15 wk | Vit D_3_ 400 IU + Ca carbonate1200 mg energy (restriction diet) | 30 | mm Hg | 112.4 | −4.1 | −6.5, −1.7 | −2.5 | −6.2, 1.2* | 0.18 | C
Major 2007^202^ Quebec City [17209177] | 43 (5.5), Women | SBP | 2° | 15 wk | Placebo energy(restriction diet) | 33 | | 109.5 | −1.6 | −4.2, 1.0 | | | | C
DIASTOLIC BLOOD PRESSURE
Margolis 2008^211^ WHI [18824662] | 50–79, Women | DBP | 2° | 6.1 y | Vit D_3_ 400 IU + Ca carbonate1000 mg | 18,176 | mm Hg | 76^A^ | −0.2%^A^ | −0.4, −0.02 | +0.11 | −0.04, +0.27 | 0.14 | B
Margolis 2008^211^ WHI [18824662] | 50–79, Women | DBP | 2° | 6.1 y | Placebo | 18,106 | | 76^A^ | −0.6%^A^ | −0.8, −0.4 | | | | B
Major 2007^202^ Quebec City [17209177] | 43 (5.5), Women | DBP | 2° | 15 wk | Vit D_3_ 400 IU + Ca carbonate1200 mg (energy restriction diet) | 30 | mm Hg | 74.9 | −3.0 | −4.8, −1.2 | 0 | −2.7, 2.7* | 1.0 | C
Major 2007^202^ Quebec City [17209177] | 43 (5.5), Women | DBP | 2° | 15 wk | Placebo(energy restriction diet) | 33 | | 75.2 | −3.0 | −5.0, −1.0 | | | | C

A Hsia 2007^199^ [17309935]

The WHI trial of a combined vitamin D_3_ 400 IU and calcium carbonate 1000 mg supplement daily versus placebo had methodological quality B for the blood pressure outcome. The 36,282 women were postmenopausal (age 50–79 y) with a background calcium intake on average of about 1150 mg/day (from diet and supplements).211 On average, the women had normal blood pressure and were allowed to take additional concurrent calcium and vitamin D supplements. At 74 months, the women’s mean systolic blood pressure had risen and diastolic blood pressure had fallen in both trial arms (by less than about 2 mm Hg each at 2 years199). The absolute changes were not significantly different in the women assigned to the supplement than placebo (net difference 0.2 mm Hg systolic and 0.1 mm Hg diastolic). In subgroup analyses there was no differences in results by age, ethnicity, baseline total calcium intake, baseline diagnosis of hypertension, or a variety of other factors.

The C quality trial of combined vitamin D and calcium, performed in Quebec City, recruited premenopausal women (mean age 43 y) with low calcium intake (800 mg calcium per day) who did not have severe hypertension (blood pressure over 160/95 mm Hg).202 The mean baseline calcium intake was 704 mg/day. On average, the 63 women had normal blood pressure. They were given either combined vitamin D_3_ 400 IU and calcium carbonate 1200 mg daily or placebo. All women were on an energy restriction diet with a 700 kcal/day deficit. At 15 weeks, systolic and diastolic blood pressures were reduced in both study groups; systolic blood pressure was reduced by 2.5 mm Hg more in women on vitamin D and calcium than placebo, but this difference was not statistically significant. Diastolic blood pressure was reduced by the same amount in both groups. No subgroup analyses were reported. The study was limited by a 25 percent dropout rate due to lack of compliance with the diet and exercise portion of the trial, without performing an intention to treat analysis, an adequate description of the study methods, or a complete statistical analysis.

Findings per intake level

Both trials used similar doses, vitamin D_3_ 400 IU and calcium carbonate 1000 or 1200 mg daily. The background calcium intake was lower in the study of premenopausal women (800 mg/day) than the WHI trial (1150 mg/day). The WHI trial found no significant difference in (lack of) effect in subgroups with different baseline total calcium intake.

Findings by age and sex

Both the one small, short term, C quality trial of premenopausal women and the 6 year WHI trial of postmenopausal women found no effect. The WHI trial also found no difference in effect in subgroups of women based on age. No trials of men were found.

Findings by life stage

- 0–6 mo Not reviewed
- 7 mo–2 y Not reviewed
- 3–8 y Not reviewed
- 9–18 y Not reviewed
- 19–50 y One small trial that included women mostly within this life stage found no significant effect of combined vitamin D and calcium supplementation.
- 51 – 70 y One large trial that included women mostly within this life stage found no significant effect of combined vitamin D and calcium supplementation.
- ≥71 y The WHI trial included some women within the life stage, but no study adequately evaluated this life stage.
- Postmenopause All women in the WHI trial were postmenopausal. See 51–71 y life stage.
- Pregnant & lactating women Not reviewed

### Combined Vitamin D and Calcium and Bone Mineral Density or Bone Mineral Content

For bone health outcomes (e.g., bone mineral density, fracture, fall or muscle strength), we relied on a recent comprehensive systematic review performed by the Ottawa EPC (Table 34).6 Because the Ottawa’s EPC report did not have separate analyses on the effect of vitamin D supplementation alone, the results for the effect of vitamin D alone or in combination with calcium supplementation were presented in this section.

The Ottawa EPC report was updated with literature published between January 2006 and April 2009, selected according to our eligibility criteria. For adults, we included only BMD indices. For children, we included only BMC indices. Only RCTs with duration more than 1 year qualified for inclusion.

Synopsis

One RCT found that, compared to placebo, there was no significant effect of supplementation with vitamin D_3_ (200 IU/d) plus calcium (1000 mg/d) on BMC changes in healthy girls, between 10 and 12 years.

Overall, findings from the Ottawa EPC report showed that vitamin D_3_ (≤800 IU/d) plus calcium (~500 mg/d) supplementation resulted in small increases in BMD of the spine, total body, femoral neck and total hip in predominantly populations of late menopausal women.6 Two of the three new RCTs showed consistent findings in postmenopausal women, comparing vitamin D_3_ or D_2_ (300 or 1000 IU/d, respectively) plus calcium (1200 mg/d) to placebo.

Detailed presentation

(Table 34, 104 & 105)

Table 104 Combined vitamin D and calcium and bone mineral density/content: Characteristics of RCTs published after the Ottawa EPC report

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Cheng 2005^212^ Jyvaskyla, Finland (62°24′N) [16280447] | - Health status; - Mean age (range), y; - Male (%) | Healthy 11.2 (10–12) 0 | Diet Vit D: 100 IU/d Ca: 670 mg/d | Vit D_3_ 200 IU/d + Ca carbonate 1000 mg/d vs. placebo | 65% completed intervention with >50% compliance
Bolton-Smith 2007^213^ (UK 54°N) [17243866] | - Health status; - Mean age (range), y; - Male (%) | Healthy (assumed postmenopausal) 68 (≥60) 0 | 25(OH)D: 59.4 nmol/L Ca: 1548 mg/d | Vit D_3_ 400 IU/d + Elemental Ca 100 mg/d vs. placebo | Good supplement adherence based on pill count (median, 99; IQE 97.3–99.8%). | Noncompliant women were excluded.
Zhu 2008^214^ CIFOS Western Australia [18089701] | - Health status; - Mean age (SD), y; - Male (%) | nd (assumed postmenopausal) 74.8 (2.6) 0 | 25(OH)D: 68.0 nmol/L Ca: 1010 mg/d | Vit D_2_ 1000 IU/d + Ca citrate 1200 mg/d vs. placebo | No differences in adherence among groups (81–89% by tablet counting)
Moschonis 2006^215^ Greece (31°N) [17181890] | - Health status; - Mean age (range), y; - Male (%) | Postmenopausal 61 (55–65) 0 | Diet Vit D: 23.6 IU/d Ca 680 mg/d | Vit D_3_ 300 IU/d + Ca 1200 mg/d (from low fat dairy products) vs. control (usual diet) | Dairy group 93% (assessed via information obtained at the biweekly sessions | Control group had no intervention (or usual diet) so compliance issue not applicable

Table 105 Combined vitamin D and calcium and bone mineral density/content: Results of RCTs published after the Ottawa EPC report

Author Year Study Name PMID | Life Stage | Outcome | 1°/2° | Mean Followup, mo | Interventions, Daily Dose | No. Analyzed | Unit | Baseline | Change | Change 95% CI | Net Diff | Net Diff 95% CI | P Btw | Study Quality
Cheng 2005^212^ [16280447] | 10–12 y girls | BMC | 1° | 24 | Vit D 200 IU + Ca carbonate 1000 mg | 46 | kg | 1.3 | 34.7% | 34.3%, 35.1% | −0.3% | −0.8, 0.2^A^ | NS | C
Cheng 2005^212^ [16280447] | 10–12 y girls | BMC | 1° | 24 | Placebo | 39 | | 1.3 | 35.0% | 34.6%, 35.4% | | | | C
Bolton-Smith 2007^213^ [17243866] | Postmenopausal women | Femoral neck BMD | nd | 24 | Vit D_3_ 400 IU + Elemental Ca 100 mg | 50 | mg/cm^2^ | nd | +1.9 | −6.5, 10.3 | +1.2 | −12.6, 15.0^A^ | NS | B
Bolton-Smith 2007^213^ [17243866] | Postmenopausal women | Femoral neck BMD | nd | 24 | Placebo | 56 | | nd | +0.7 | −10.2, 11.6 | | | | B
Zhu 2008^214^ Australia CIFOS [18089701] | Postmenopausal women | Hip BMD | 1° | 60 | Vit D_2_ 1000 IU + Ca citrate 1200 mg | 39/33^B^ | mg/cm^2^ | 783 | nd | | +2.2% | 1.9, 2.5 | 0.05 | B
Zhu 2008^214^ Australia CIFOS [18089701] | Postmenopausal women | Hip BMD | 1° | 60 | Placebo | 41/36^B^ | | 828 | nd | | | | | B
Moschonis 2006^215^ [17181890] | Postmenopausal women | Total body BMD | 1° | 12 | Vit D_3_ 300 IU + Ca 1200 mg (from low fat dairy products) | 39 | mg/cm^2^ | 1.13 | 1.5% | 0.9%, 2.2% | +2.2% | 1.3, 3.1^A^ | <0.05 | C
Moschonis 2006^215^ [17181890] | Postmenopausal women | Total body BMD | 1° | 12 | Control (usual diet) | 36 | | 1.12 | −0.7% | −1.4%, −0.1% | | | | C

A Estimated from reported data.

B Baseline/follow-up number of subjects analyzed

One RCT compared the effect of vitamin D_3_ (200 IU/d) plus calcium (1000 mg/d) supplementation to placebo on bone indices in healthy girls, aged 10 and 12 years.212 The mean background dietary calcium intake was 670 mg/d. The intention-to-treat analyses showed that after 2 years of supplementation, there was no significant difference in the BMC changes between girls who received vitamin D plus calcium supplement or placebo. The methodological quality of this study was rated C, due to underpower and low compliance rate.

Three RCTs (two were rated B and one was rated C) examined the effect of vitamin D plus calcium supplementation on BMD changes. All three trials were conducted in postmenopausal women. However, the doses of vitamin D and calcium combinations varied. One RCT used daily dose of 400 IU vitamin D_3_ plus 100 mg elemental calcium for 2 years 213 The second RCT used daily dose of 1000 IU vitamin D_2_ plus 1200 mg calcium citrate for 5 years.214 The third RCT used a daily dose of vitamin D_3_ 300 IU plus calcium citrate 1200 mg from calcium supplemented low-fat dairy products for 1 year.215 The latter two RCTs resulted in a significant increase in hip or total BMD comparing vitamin D plus calcium supplementation to placebo.214,215 The one RCT that did not show significant change in femoral neck BMD comparing vitamin D plus calcium supplementation to placebo used a substantially lower dose of calcium (100 mg/d) than the other two RCTs.

In Ottawa EPC report - Bone Mineral Density and women of reproductive age, postmenopausal women, and older men

Overall, there is good evidence that vitamin D_3_ plus calcium supplementation resulted in small increases in BMD of the spine, total body, femoral neck and total hip. Based on included trials, it was less certain whether vitamin D_3_ supplementation alone has a significant effect on BMD.

Seventeen RCTs evaluated the effect of supplemental vitamin D_2_ or D_3_ on BMD, predominantly in populations of late menopausal women. Only one small RCT included premenopausal women, and two trials included older men (> 60 years). Most trials were two to three years in duration and used vitamin D doses of ≤ 800 IU daily. Most trials used vitamin D_3_ and also included calcium 500 mg as a cointervention

Meta-analysis results of 17 RCTs of vitamin D_3_ plus calcium versus placebo were consistent with a small effect on lumbar spine, femoral neck, and total body BMD. The WHI trial found a significant benefit of 400 IU vitamin D_3_ plus 1000 mg calcium supplementation on total hip BMD. However, when the effect of vitamin D_3_ plus calcium versus calcium alone supplementation is assessed, no significant increase in BMD was observed with either intervention, suggesting vitamin D_3_ may be of less benefit in calcium replete postmenopausal women. Vitamin D_3_ alone versus placebo did not result in a significant increase in BMD in postmenopausal women, except in one trial that noted an increase in femoral neck BMD. Only a few trials reported the impact of baseline serum 25(OH)D concentrations on BMD and in all of these trials, baseline 25(OH)D concentration was not associated with increased BMD.

Findings by life stage

- 0–6 mo No data
- 7 mo–2 y No data
- 3–8 y No data
- 9–18 y One RCT showed that, compared to placebo, there was no significant effect of vitamin D_3_ (200 IU/d) plus calcium (1000 mg/d) on BMC changes in healthy girls, aged between 10 and 12 years old.
- 19–50 y No data
- 51–70 y No new data since the Ottawa EPC report
- ≥71 y No new data since the Ottawa EPC report
- Postmenopause Findings from the Ottawa EPC report showed that vitamin D_3_ (≤800 IU/d) plus calcium (~500 mg/d) supplementation resulted in small increases in BMD of the spine, total body, femoral neck, and total hip in predominantly populations of late menopausal women. Two of the three new RCTs showed a significant increase in hip or total BMD in postmenopausal women, comparing D_3_ or D_2_ (300 or 1000 IU/d, respectively) plus calcium (1200 mg/d) to placebo.
- Pregnant & lactating women No new data since the Ottawa EPC report

## How does dietary intake of vitamin D from fortified foods and vitamin D supplementation affect serum 25(OH)D concentrations (arrow 4)?

The evidence for this question comes from studies identified in our literature search that crossed vitamin D terms with various outcomes terms. Studies that addressed this question but do not report any of the outcomes of interest would not have been identified in this manner. Because the availability of serum 25(OH)D concentration is unlikely to be adequately indexed in the Medline citation, it would be difficult to comprehensively search the literature for this question. To do so would require retrieving all vitamin D supplements full text articles (in excess of 10,000) to look for serum 25(OH)D concentration data. Given that there is no plausible reason for a systematic bias of studies of a specific outcome choosing to report serum 25(OH)D concentration, we believe that the evidence found, while not comprehensive, is a small but representative random sample. Only RCTs were included for this question. RCTs of different regimens but with the same dose of vitamin D supplementation were excluded (e.g., comparison of daily, weekly versus monthly dose).

This question was also addressed in the Ottawa EPC report.6 When appropriate, we extracted relevant data from the Ottawa EPC report to be incorporated into our analyses.

### RCTs on Dietary Intakes of Vitamin D From Fortified Foods and Serum 25(OH)D Concentrations

Synopsis

Our updated search did not identify new RCT evaluating the effect of food fortification on serum 25(OH)D concentrations since the Ottawa EPC report.6 The Ottawa EPC report concluded that there is “good” evidence that dietary intake of vitamin D increases serum 25(OH)D concentrations among adults.

Detailed presentation

Ottawa EPC report –Adults

There were eleven RCTs (n=1281) of which seven (n=668) permitted a quantitative analysis. Ten of eleven trials found a significant effect of dietary intake from foods fortified with vitamin D on serum 25(OH)D concentrations. There was significant heterogeneity of the treatment effect. Potential sources of heterogeneity are the different 25(OH)D assays used (two studies each used HPLC, RIA or CPBA, and one study did not report the assay), the dietary vehicles used, and study populations. The increase in serum vitamin D concentration in the seven trials ranged from 15 (95 percent CI 11, 18) to 40 (95 percent CI 25, 55) nmol/L (fortification consisting of 100–1000 IU of vitamin D).

There can be a potential confounding of the data by the food source, the assay used to measure 25(OH)D and potential differences in the bioavailability and/or metabolism of vitamin D_2_ versus vitamin D_3_. Most studies in this review used dairy products as the source of fortified food. It is important to note that there is potential for study contamination through altered intake of other nutrients such as calcium, phosphate and acid load that can affect the study outcomes.

### RCTs on Vitamin D Supplementation and Serum 25(OH)D Concentrations

Synopsis

Because the availability of serum 25(OH)D concentration is unlikely to be adequately indexed in the Medline citation, it would be difficult to comprehensively search the literature for this question. We believe that studies summarized here is a small but representative random sample of all available data.

We plot the net changes in serum 25(OH)D concentration against the doses of vitamin D supplementation using data from 26 RCTs with 28 comparisons in adults. Only RCTs of daily vitamin D_3_ supplementation (doses ranged from 200 to 5000 IU/d) alone or in combination with calcium supplementation (doses ranged from 500 to 1550 mg/d) that provided sufficient data for the calculations were included in the plot. It is important to note that the studies had varied compliance rates in the vitamin D intake; limited or no adjustment for skin pigmentations, calcium intake, or background sun exposure; different vitamin D assay methodologies and measurement (both intra- and interassay) variability. All these factors increase the heterogeneity and limit the usefulness of an overall summary estimate for an intake dose response in serum 25(OH)D concentration. Nonetheless, the relationship between increasing doses of vitamin D_3_ with increasing net change in 25(OH)D concentration was evident in both adults and children (Figure 23). It was also apparent that the dose-response relationships differ depending on study participants’ serum 25(OH)D status (≤40 vs. >40 nmol/L) at baseline (Figure 24), and depending on duration of supplementation (≤3 vs. >3 months) (Figure 25).

Figure 23 Relationship between doses of Vitamin D3 supplementation and net changes in serum 25(OH)D concentrations in RCTs

Legends: Each empty circle represents one study. The area of the circle is proportional to the inverse of the within-study variances. Typically, the larger the bubble, the larger the sample size and the smaller the standard error of the changes in 25(OH)D.

Figure 24 Relationship between doses of Vitamin D_3_ supplementation and net changes in serum 25(OH)D concentrations in RCTs by baseline vitamin D status among adults

Legends: Each empty circle represents one study. The area of the circle is proportional to the inverse of the within-study variances. Typically, the larger the bubble, the larger the sample size and the smaller the standard error of the changes in 25(OH)D.

Figure 25 Relationship between doses of Vitamin D_3_ supplementation and net changes in serum 25(OH)D concentrations in RCTs by duration of supplementation among adults

Legends: Each empty circle represents one study. The area of the circle is proportional to the inverse of the within-study variances. Typically, the larger the bubble, the larger the sample size and the smaller the standard error of the changes in 25(OH)D.

Vitamin D_2_ supplementation was more commonly used in RCTs of infants and pregnant or lactating women, than vitamin D_3_ supplementation. Results showed that supplementation of vitamin D_2_ significantly increased 25(OH)D concentrations in infants, lactating mothers and in cord blood.

Detailed presentation

(Table 106; Figures 23, 24 & 25)

Table 106 The relationship between vitamin D_3_ daily doses and changes in 25(OH)D concentrations in RCTs

Author | Year | Life stage | Base 25(OH)D, nmol/L | Vit D_3_ dose (IU/d) | Ca dose (mg/d) | Duration (mo) | Vit D_3_ ± Ca Group | | | Placebo or Ca Group
Author | Year | Life stage | Base 25(OH)D, nmol/L | Vit D_3_ dose (IU/d) | Ca dose (mg/d) | Duration (mo) | n | Mean change from baseline | SD | n | Mean change from baseline | SD
Bjorkman | 2008^209^ | 71+ | 23 | 400 | 0 | 6 | 60 | 26.5 | 11.8 | 59 | 1.9 | 10.2
Bjorkman | 2008^209^ | 71+ | 23 | 1200 | 0 | 6 | 63 | 49.1 | 19.5 | 59 | 1.9 | 10.2
Blum | 2008^216^ | 71+ | 73 | 700 | 500^A^ | 12 | 132 | 48.5 | 35.3 | 125 | 9.3 | 21.5
Bunout | 2006 80 | 71+ | 40 | 400 | 800^A^ | 9 | 46 | 33.4 | 14.3 | 46 | 3.5 | 10.0
Chapuy | 1992 217 | 71+ | 36 | 800 | 1200 | 18 | 73 | 65.0 | 16.5 | 69 | −4.5 | 13.5
Chel | 2008^218^ | 71+ | 23 | 600 | 0 | 4 | 46 | 46.9 | 15.4 | 45 | 0.3 | 12.2
Deroisy | 2002 219 | 71+ | 28 | 200 | 500^A^ | 3 | 50 | 14.7 | 10.0 | 50 | 4.5 | 10.0
Himmelstein | 1990 220 | 71+ | 45 | 2000 | 0 | 1.5 | 15 | 39.7 | 15.7 | 15 | −2.7 | 13.4
Kenny | 2003 221 | 71+ | 62 | 1000 | 500^A^ | 6 | 29 | 22.3 | 10.1 | 31 | −2.5 | 11.4
Krieg | 1999 222 | 71+ | 29 | 880 | 500 | 24 | 34 | 36.5 | 14.0 | 38 | −15.0 | 11.1
Pfeifer | 2000 223 | 71+ | 25 | 880 | 1200^A^ | 2 | 74 | 40.5 | 27.0 | 74 | 18.3 | 20.9
Pfeifer | 2001 97 | 71+ | 25 | 800 | 1200 | 2 | 73 | 39.2 | 22.4 | 72 | 19.7 | 23.8
Sorva | 1991 224 | 71+ | 11 | 1000 | 1000 | 10 | 5 | 44.6 | 28.9 | 10 | −1.4 | 2.3
Zhu | 2008 214 | 71+ | 68 | 1000 | 1200^A^ | 60 | 29 | 36.2 | 27.5 | 34 | −2.9 | 27.4
Barnes | 2006 225 | adults | 52 | 600 | 1500^A^ | 2 | 12 | 38.6 | 15.1 | 15 | −7.2 | 11.3
Bolton-Smith | 2007 213 | adults | 60 | 400 | 100 | 24 | 50 | 12.0 | 15.1 | 56 | −8.2 | 14.3
Dawson-Hughes | 1997^226^ | adults | 74 | 700 | 500 | 36 | 145 | 35.2 | 32.6 | 167 | −2.1 | 22.7
Harris | 2002 227 | adults | 55 | 800 | 0 | 2 | 27 | 22.3 | 14.0 | 23 | −4.6 | 6.3
Heaney | 2003 228 | adults | 71 | 1000 | 0 | 5 | 16 | 12.0 | 16.0 | 16 | −11.4 | 17.6
Heaney | 2003 228 | adults | 71 | 5000 | 0 | 5 | 17 | 91.9 | 37.6 | 16 | −11.4 | 17.6
Heikkinen | 1998 229 | adults | 26 | 300 | 500^A^ | 12 | 18 | 9.4 | 10.9 | 18 | −3.3 | 6.4
Honkanen | 1990 230 | adults | 31 | 1800 | 1550 | 2.75 | 55 | 39.5 | 12.1 | 60 | −13.1 | 9.2
Jensen | 2002 231 | adults | 41 | 400 | 1450 | 36 | 33 | 34.6 | 23.2 | 33 | 16.5 | 28.2
Nelson | 2009^232^ | adults | 62 | 800 | 0 | 12 | 55 | 35.3 | 23.2 | 31 | 10.9 | 16.9
Orwoll | 1988 233 | adults | 58 | 1000 | 1000 | 12 | 46 | 25.0 | 19.1 | 46 | 3.0 | 19.1
Patel | 2001 234 | adults | 72 | 800 | 0 | 12 | 35 | 8.4 | 13.1 | 35 | −9.2 | 12.8
Riis | 1984 235 | adults | 41 | 2000 | 500 | 12 | 8 | 87.5 | 14.1 | 7 | −5.0 | 23.8
Trang | 1998 236 | adults | 42 | 4000 | 0 | 0.5 | 24 | 23.3 | 17.5 | 24 | 3.0 | 19.8
Chan | 1982 237 | children | 43 | 400 | 0 | 6 | 30 | 22.5 | 6.6 | 30 | −2.5 | 6.6
El-Hajj (Fuleihan) | 2006 35 | children | 35 | 200 | 0 | 12 | 58 | 7.5 | 19.8 | 55 | 5.0 | 18.8
El-Hajj (Fuleihan) | 2006 35 | children | 35 | 2000 | 0 | 12 | 55 | 59.9 | 67.1 | 55 | 5.0 | 18.8

A Calcium supplement was given to all patients

The format of this table has been slightly modifies to fit each RCT in one line.

The results from 26 RCTs with 28 comparisons in adults and two RCTs with three comparisons in children evaluating the effect of vitamin D_3_ supplementation alone or in combination with calcium supplementation on serum 25(OH)D concentrations were shown in Table 106. Most of the data were extracted directly from the Ottawa EPC report. In adults, the doses of vitamin D_3_ ranged from 200 to 5000 IU/d, and the doses of calcium supplementation ranged from 500 to 1550 mg/d across the 25 comparisons. In children, the doses of vitamin D_3_ ranged from 200 to 2000 IU/d across the three comparisons. Duration of supplementation ranged from 0.5 to 60 months. Study populations and baseline vitamin D concentrations varied across these comparisons.

Ottawa EPC report – Infants

Seven RCTs included infants and few trials used vitamin D_3_ supplementation. One RCT concluded that 200 IU of vitamin D_2_ may not be enough to prevent vitamin D deficiency in those infants residing at northern latitudes. A dose-response relationship was noted in this trial (100, 200, 400 IU/day). Consistent responses to vitamin D supplementation were noted across the seven trials, and some trials suggested that infants who are vitamin D deficient may respond differently and require higher doses of vitamin D to achieve serum 25(OH)D concentrations within the normal range.

Ottawa EPC report - Pregnant or lactating women

There were six small RCTs of vitamin D supplementation in pregnant or lactating women. No randomized trials studied the effect of 400 IU vitamin D_3_/d. Three trials used 1000 IU vitamin D_2_/d and one trial used 1000 IU/d of vitamin D_3_. Supplementation of vitamin D_2_ 1000–3600 IU/d and vitamin D_3_ 1000 IU/d resulted in significant increases in serum 25(OH)D concentrations in lactating mothers and in cord blood. One trial found that supplementation of lactating mothers with 1000 IU vitamin D_2_/d during winter months did not significantly increase serum 25(OH)D concentrations in the infants.

Ottawa EPC report - Children and adolescents

There were four trials that examined the effect of vitamin D on serum 25(OH)D concentrations in children or adolescents with doses ranging from 200 to 2000 IU of vitamin D_3_ per day and 400 IU of vitamin D_2_. There were consistent increases in serum 25(OH)D concentrations ranging from 8 nmol/L (200 IU/d), 16.5 (with 600 IU D_3_/d) to 60 nmol/L (2000 IU of vitamin D_3_/d).

Ottawa EPC report - Premenopausal women and younger men

Ten small trials included premenopausal women and younger males. Three trials compared vitamin D_2_ to vitamin D_3_ in healthy young adults. Two of the three trials used RIA, and one used HPLC to measure serum 25(OH)D concentrations The doses of vitamin D_3_ ranged from 600 to 10,000 IU/day and vitamin D_2_ (4000 IU/d or 50,000 to 100,000 for single dose).

Three trials found that supplementation with vitamin D_2_ and D_3_ in healthy adults may have different effects on serum 25(OH)D concentrations. One trial compared 100,000 IU vitamin D_2_ given orally versus injection and found a greater variability in response with the intramuscular preparation. There appeared to be dose-response effect in those trials that used multiple doses of vitamin D_3_, although there were insufficient data to perform a meta-analysis.

Ottawa EPC report - Postmenopausal women and older men

Forty-four trials were conducted exclusively in postmenopausal women and older men, with 14 of these in elderly populations living in long-term care or nursing homes. One trial enrolled only women in early menopause (n=129). Doses of vitamin D_3_ ranged from 100 to 4000 IU/day and vitamin D_2_ was 9000 IU/day. One trial was conducted in African American women.

One trial found that wintertime declines in serum 25(OH)D concentrations were prevented with 500 IU vitamin D_3_ per day. A dose response with increasing doses of vitamin D_3_ was noted for serum 25(OH)D concentrations. There was variability in response to similar doses across trials that may have been due to differences in serum 25(OH)D assays or baseline 25(OH)D concentrations. Similarly, although some trials reported a greater response to vitamin D in populations that were vitamin D deficient at baseline compared to those who were not, there were insufficient data on which to base a definitive conclusion on this point.

## Outcomes for Tolerable Upper Intake Levels

We included only clinical outcomes of tolerable upper intake levels, such as all-cause mortality, cancer (incidence and mortality), soft tissue calcification, renal outcomes, and adverse events reported in RCTs.

Results of all-cause mortality and cancer have been described in previous sections. In brief, we did not find vitamin D and/or calcium associated with an increased risk of mortality. For cancer risk, there were some observational studies reporting high calcium intake may be associated with an increased risk of prostate cancer (see “Prostate cancer” in “Calcium and cancer” section). We did not identify any studies on soft tissue calcification and tolerable upper intake levels.

### Renal Outcomes

The WHI trial on women aged 50 to 79 years, examined the effect of vitamin D_3_ 400 IU (the Recommended Dietary Allowance for women aged 50 to 70 years and below the 600 IU recommended intake for women > 70 years) in combination with 1000 mg calcium carbonate versus placebo and found an increase in the risk of renal stones (Hazard Ratio 1.17 95 percent CI 1.02, 1.34), corresponding to 5.7 events per 10,000 person years of exposure.71 It should be noted that women in both groups were allowed to take additional vitamin D supplements up to 600 IU and later 1000 IU per day and calcium supplements up to 1000 mg per day. The baseline total calcium intakes (from foods and supplements) were high: 34 percent consumed less than 800 mg/d, 26 percent consumed 800 to 1200 mg/d, and 40 percent consumed more than 1200 mg/d. A prior publication from WHI trial provided the same data on the risk of renal stones was also included in the Ottawa EPC report.

No studies were identified that evaluated the effect of vitamin D, calcium, or combined vitamin D and calcium on other renal outcomes.

### Adverse Events Reported in RCTs

The reporting of adverse events in RCTs was generally inadequate, and most trials were not adequately powered to detect adverse events. Among the 63 RCTs included in this report, 47 did not report information on adverse events.

Five RCTs (in 6 publications) that enrolled a total of 444 subjects reported no adverse events during the trial periods.35,51,227,238,239 Of these, one RCT administered combination of vitamin D_2_ (1600 or 3600 IU/d) and vitamin D_3_ (400 IU/d) supplements for 3 months, two RCTs administered vitamin D supplements (type of vitamin D not reported) with doses ranging from 200 to 2000 IU/d for 3 weeks or 1 year, one RCT used high-dose intermittent vitamin D_3_ supplement (120,000 IU sachets given 3 times, every 2 weeks, for 6 weeks), and one RCT administered 1200 IU/d vitamin D_2_ supplement for 5 years.

Eleven RCTs reported at least one adverse event (Table 107). Excessive gas, bloating, and gastrointestinal discomforts were reported to be associated with calcium supplementation (doses ranged from 600 to 1000 mg/d). Other RCTs of vitamin D (doses ranged from 400 to 5714 IU/d vitamin D_3_ or ranged from 5000 to 10,000 vitamin D_2_) and/or calcium supplementations (doses ranged from 200 to 1500 mg/d) reported few cases of gastrointestinal disruption such as constipation, diarrhea, upset stomach, musculoskeletal soreness, primary hyperparathyroidism, hypercalcemia, renal calculi and craniotabes. One RCT reported some adverse events that required hospital admission, including retrosternal pain, a non-ST elevation myocardial infarction and a transient ischemic attack (all 3 cases in vitamin D 400 IU/d plus exercise training group) and one case of acute cholecystitis (in calcium, vitamin D plus exercise training group).80 Another RCT reported that “there were no significant differences between the vitamin D and the control groups in the rate of incident cancer and vascular disease (ischemic heart disease and stroke)” (actual data not provided), and one participant died during the study.98 However, these adverse events may or may not be associated with vitamin D and/or calcium supplementation in this study. Also described earlier in the “Renal outcomes” section, the WHI trial examined the effect of vitamin D_3_ 400 IU in combination with 1000 mg calcium carbonate versus placebo and found an increase in the risk of renal stones (Hazard Ratio 1.17 95 percent CI 1.02, 1.34), corresponding to 5.7 events per 10,000 person years of exposure.71

Table 107 Adverse events reported in RCTs

Author Year | N enrolled | Vit D dose (IU/d) | Ca dose (mg/d) | Duration | Adverse Event data (n=case#)
Yamamoto 1995 117 | 471 | 0 | 1000 | 6 mo | Comparing calcium group to the placebo group, excessive gas and bloating were more frequently reported by white women at 3 months and by whites, in general, at 6 months, and white men reported more loose stools at 6 months.
Moschonis 2006 215 | 112 | 300 D_3_ | 600 or 1200 | 12 mo | Bloating, constipation and intestinal discomfort apparently related to the calcium supplement
Bunout 2006 80 | 96 | 400 | 800 | 9 mo | Adverse events that required hospital admission: Vit D plus exercise training group (n=3): retrosternal pain, a non-ST elevation myocardial infarction and a transient ischemic attack. Calcium, Vit D plus exercise training group (n=1): acute cholecystitis
Wactawski-Wende 2006 71 | 36282 | 400 | 1000 | 7 y | The WHI trial found an increase in the risk of renal stones (Hazard Ratio1.17 95% CI 1.02, 1.34), corresponding to 5.7 events per 10,000 person years of exposure.
Burleigh 2007 81 | 205 | 800 D_3_ | 1200 | Median 1 mo | Hypercalcemia (n=2)
Lappe 2008 208 | 5201 | 800 | 200 | 8 wks | GI disruption such as constipation, diarrhea, upset stomach (4%), and musculoskeletal soreness (0.9%)
Brooke 1980 34 | 126 | 1000 | 0 | 3^rd^ trimester only | Vit D group (craniotabes, n=2), placebo group (hypocalcemia, n=5; craniotabes, n=6)
Lappe 2007 52 | 1180 | 1000 D_3_ | 1400–1500 | 4 y | Renal calculi in placebo (n=1), renal calculi in calcium only (n=3), renal calculi in calcium plus vit D (n=1)
Mastaglia 2006 240 | 65 | 5000 or 10,000 D_2_ | 500 | 3 mo | Hypercalciuria (n=1) in control group
Zhu2008^98^ | 256 | 1000 D_2_ | 1200 | 12 mo | There were no significant differences between the vitamin D and the control groups in the rate of incident cancer and vascular disease (ischemic heart disease and stroke). There were 8 and 5 adverse events in vitamin D and the control groups, respectively. One participant in the vitamin D group had mild asymptomatic hypercalcemia one occasion. No case of renal calculus was reported. 1 participant was deceased during the study.
Sneve 2008^50^ | 445 | Group 1: 2 capsules of vitamin D_3_ each, 20000 IU taken twice a week (Monday and Thursday): ~5714 IU/d Group 2: 1 capsules of vitamin D_3_ each20,000 IU taken twice a week (Monday and Thursday): ~2857 IU/d | 500 | 12 mo | Primary hyperparathyroidism (n=2), increase in serum calcium to 2.62 mmol/L (n=1), transient increases in serum calcium > 2.59 mmol/L (n=4). 317 other adverse events were recorded, most of them related to GI discomfort. There were no significant differences between the treatment groups regarding adverse events.

Ottawa EPC report

A total of 22 trials reported data on toxicity-related outcomes, 21 of which used doses above 400 IU/d. Toxicity results from trials with intakes of vitamin D above current reference intakes varied and this may have been related to different doses, baseline characteristics of populations or exposure times. Most trials excluded subjects with renal insufficiency or hypercalcemia, were of small sample sizes and had short durations of exposure to vitamin D. Event rates were low across trials in both the treatment and placebo arms.