# Evidence Tables: R-Z

## Reid 2005

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
15827103 | Reid 2005 | RCT | 5 y post-menopausal, age >55 y | Osteoporosis therapy, Ca supplement, major ongoing disease, 25(OH)D<10 μg/L (25 nmol/L), metabolic bone disease, regular users of HRT, anabolic steroids, glucocorticoids, bisphosphonates, LS bone density z score<-2 | ~2000 | Same as Bolland 2008 | Govt (suppl supplied by industry) | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
15827103 | Reid 2005 | RCT | Auckland, New Zealand (36.5°S) | 1471 | 1471 (ITT), 153 withdrew prior to 30 months | 74 (~4.2) | ≥55 y | 0 | nd | BMI 26.4 | healthy | 25(OD)D≥25 nmol/L

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | | | | nd
15827103 | Reid 2005 | Dietary calcium intake | nd | nd | nd | | | | | Dietary calcium 857 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
18198394 | Reid 2005 | Ca supplement | Calcium citrate (Citracal) | 1 g (elemental) | 5 years | 2 x 200 mg before breakfast; 3 x 200 mg evening
| | Identical placebo
Co-intervention(s) * : | | | None
Compliance/Adherence: | | | Calcium: 396 (54%) alive, continuing followup, continuing intervention at 5 years. Overall compliance 55% Placebo: 443 (60%) alive, continuing followup, continuing intervention at 5 years. Overall compliance 58%

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
18198394 | Reid 2005 | 2° | Weight | Kg, BMI
| | 2° | BP | SBP, DBP

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
18198394 | Reid 2005 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
18198394 | Reid 2005 | Demographics (e.g., age, gender, race, education)? | No
18198394 | Reid 2005 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No
18198394 | Reid 2005 | Medical conditions
18198394 | Reid 2005 | Medication
18198394 | Reid 2005 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
18198394 | Reid 2005 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | No
18198394 | Reid 2005 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline SD * | Delta ** | Final or Delta SE | Net difference | Net difference CI/SE/SD * | P between
18198394 | Reid 2005 | Weight | Kg | Calcium | 30 | 732 | 66.9 | 11.5 | −0.368 | 0.132 | 0 | | 0.93
18198394 | Reid 2005 | Weight | Kg | Placebo | | 739 | 67.1 | 11.8 | −0.369 | 0.134
| | BMI | kg/m ^ 2 ^ | Calcium | 30 | 732 | 26.5 | 4.3 | +0.01 | 0.05 | −0.01 | | 0.83
| | BMI | kg/m ^ 2 ^ | Placebo | | 739 | 26.4 | 4.2 | +0.02 | 0.05
| | SBP | mm Hg | Calcium | 30 | 732 | 134.9 | 22.6 | 0.0 | 0.9 | −2.4 | | 0.14
| | SBP | mm Hg | Placebo | | 739 | 133.9 | 22.9 | +2.4 | 0.9
| | DBP | mm Hg | Calcium | 30 | 732 | 70.1 | 10.7 | −0.2 | 0.4 | −1.0 | | 0.13
| | DBP | mm Hg | Placebo | | 739 | 69.6 | 10.0 | +0.8 | 0.4

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “− “ sign: e.g. +2.8 or −2.8

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
18198394 | Reid 2005 | RCT | Y | Y | NA | Y | nd | Y | Y | N | Y | B
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Since these are 2° outcomes (from original study perspective), fully adjusted analyses should have been performed

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Rodriguez 2003

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
12869397 | Rodriguez 2003 | Cohort study | -residing in one of 21 states with population-based state cancer registries | -men with a history of cancer -incomplete dietary information -loss to follow-up from baseline through August 31, 1999 -those with prevalent cancer at baseline, except nonmelanoma skin cancer -those whose self report of prostate cancer could not be confirmed -extreme values of energy intake reported -leaving 15% or more of FFQ items blank, four or more out of seven dairy food questions blank, uninterpretable responses to calcium or multivitamin questions. | 1992–1993 | Cancer Prevention Study II Nutrition Cohort | Nd | KP/SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
12869397 | Rodriguez 2003 | Cohort study | United States (various) | 86,404 male participants in the CPS-II Nutrition Cohort | 65,321 | nd | 50–74 | 100% | Nd | BMI mean = 26.1 | Nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed information as possible on subject selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
12869397 | Rodriguez 2003 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | Nd | Nd | Nd | Nd | -Intake <700 mg/day of calcium: mean vitamin D intake = 168.2 IU/day -Intake <700 mg/day of calcium: mean vitamin D intake = 168.2 IU/day
| | Dietary calcium intake | FFQ (modified Block) | Diet Analysis System version 3.8a | Y, energy- adjusted correlation controlling for day-to-day variations in 24-hour recalls is 0.68 | | | | | Nd 6547130

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
12869397 | Rodriguez 2003 | Nd | Prostate cancer | Incident cases identified through self-report, verified through medical records or linkage with state cancer registries. Also through death certificates among cohort members not reporting cancer at enrollment.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
12869397 | Rodriguez 2003 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Total energy intake, total fat intake, phosphorous, total vitamin D
12869397 | Rodriguez 2003 | Demographics (e.g., age, gender, race, education)? | Yes | Age at entry, education, race
12869397 | Rodriguez 2003 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no
12869397 | Rodriguez 2003 | Medical conditions
12869397 | Rodriguez 2003 | Medication
12869397 | Rodriguez 2003 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
12869397 | Rodriguez 2003 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | No
12869397 | Rodriguez 2003 | Other | Family history of prostate cancer in brother or father

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non- cases/Total N ** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups *** | P for trend ****
12869397 | Rodriguez 2003 | Prostate cancer | Total calcium intake <700 mg/day | nd | nd | 1323 | 23,653 | 147,858 person- years | adjusted | RR | 1 | Reference | Nd | 0.02
| | | Total calcium intake 700–999 mg/day | nd | nd | 1293 | Nd | 137,184 person- years | | | 1.0 | 0.9–1.1 | Nd
| | | Total calcium intake 1000– 1499 mg/day | nd | nd | 835 | Nd | 88,023 person- years | | | 1.0 | 0.9–1.1 | Nd
| | | Total calcium intake 1500– 1999 mg/day | nd | nd | 265 | nd | 23,174 person- years | | | 1.3 | 1.1–1.5 | Nd
| | | Total calcium intake ≥2000 mg/day | nd | nd | 95 | 1,330 | 8,152 person- years | | | 1.2 | 1.0–1.6 | Nd

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
12869397 | Rodriguez 2003 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | Y | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
12869397 | Rodriguez 2003 | b) Sampling of population random or consecutive? (y/n) | nd | b) Outcome assessor blinded to exposure measurement? (y/n) | Y | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | nd
12869397 | Rodriguez 2003 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Y | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | N | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | A
Explanation for Overall Quality Grade (if not Grade A):

* Check “NA” h and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Rohrmann 2007

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17315319 | Rohrmann 2007 | Cohort study | men; completed FFQ | <35 y in 1989; baseline cancer; skipped >32 items in FFQ; <3 food items consumed per day; total energy intake outside the range of 800–5000 Kcal | 1989 | CLUE II study | government | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat...cetc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake "cetc.)
17315319 | Rohrmann 2007 | Cohort study | Washington County, Maryland | 5620 | 3892 | 53.8 (nd) | nd | 100 | 99% white | BMI 27.2 | nd | 25% used calcium supplements

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | | | | nd
17315319 | Rohrmann 2007 | Calcium intake (dietary and supplement) | 60 item Block FFQ | nd | n | | | | | 25% used calcium supplements

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17315319 | Rohrmann 2007 | primary | incident prostate cancer | Cancer Registry; death certificates; Natl Death Index

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17315319 | Rohrmann 2007 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | | energy intake; tomato; saturated fat
17315319 | Rohrmann 2007 | Demographics (e.g., age, gender, race, education)? | Yes | age
17315319 | Rohrmann 2007 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI at age 21
17315319 | Rohrmann 2007 | Medical conditions
17315319 | Rohrmann 2007 | Medication
17315319 | Rohrmann 2007 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
17315319 | Rohrmann 2007 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | No
17315319 | Rohrmann 2007 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca dose (diet & suppl combined) | No. of Event * | Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
17315319 | Rohrmann | incident prostate cancer | tertile 1 | | <685.77 mg/d | 58 | nd | adj | HR | 1.00 | | | 0.99
| | | tertile 2 | | 685.77 to 957.58 mg/d | 65 | nd | | | 0.98 | 0.72– 1.47
| | | tertile 3 | | >957.58 mg/d | 76 | nd | | | 0.99 | 0.70– 1.41

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
17315319 | Rohrmann 2007 | low-stage and high-stage prostate cancer | see Table 2 in paper

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
17315319 | Rohrmann | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | N | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories(eg quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders(other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | N
17315319 | Rohrmann | b) Sampling of population random or consecutive? (y/n) | nd | b) Outcome assessor blinded to exposure measurement? (y/n) | N | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories(eg quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders(other than age and sex)? ** (y/n) | Y | b) Loss to follow-up<20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
17315319 | Rohrmann | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Calcium intake is from combined diet and supplement; only 25% of participants used supplement; not all relevant confounders adjusted

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Ross 1997

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
9236416 | Ross 1997 | Case-cohort study | Men 45–64 yo at screening Cases: Fatal stroke Controls: 5 per case, matched for age, month of interview, neighborhood, alive at time of death of index case | History of cancer | 1986–89 | None | NCI | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or%body fat...cetc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake...cetc.)
9236416 | Ross 1997 | Case- cohort study | Shanghai, China 31° N | 18,244 | 245 cases1225 controls | nd | 45–64 | 100% | Chinese | BMI quartiles: <20, 20–<22, 22–<24.2, ≥ 24.2 | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or1,25(OH) _ 2 _ D | | | | nd | | | | nd
9236416 | Ross 1997 | Dietary calcium intake | FFQ | Chinese Food Composition Tables | nd | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
9236416 | Ross 1997 | 1° | Fatal stroke

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
9236416 | Ross 1997 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
9236416 | Ross 1997 | Demographics (e.g., age, gender, race, education)? | Yes | Age matched
9236416 | Ross 1997 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI
9236416 | Ross 1997 | Medical conditions | Yes | HTN
9236416 | Ross 1997 | Medication
9236416 | Ross 1997 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
9236416 | Ross 1997 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | Cigarettes, alcohol
9236416 | Ross 1997 | Other | Yes | Education, marital status

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥ 2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | F/up | Mean Ca level/dose | No. of Cases (Event) * | No. of Non-cases | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups *** | P for trend ****
9236416 | Ross 1997 | Fatal stroke | Calcium tertile 1 | 12 years | nd | 103 | 460 | Adjusted | RR | 1.0 | -- | | NS
| | | Calcium tertile 2 | | nd | 68 | 369 | | | 0.8 | 0.6,1.6 | NS
| | | Calcium tertile 3 | | nd | 74 | 396 | | | 1.0 | 0.8,1.4 | NS

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

MEAN DATA

THIS SHOULD ONLY APPLY TO CASE-COHORT STUDIES THAT COMPARE BASELINE VIT D/CA LEVELS BETWEEN CASES (WITH DISEASE) AND CONTROLS (WITHOUT DISEASE)

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Mean 25(OH)D Level | Vit D level CI/SE/SD* | Mean Ca intake | Ca CI/SE/SD* | P between groups
9236416 | Ross 1997 | Cases: | 12 years | Crude | 245 | | | 228 mg | | 0.38
| | Control: | | | 1225 | | | 241 mg

Duplicate one table per outcome

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
9236416 | Ross 1997 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | nd | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories(eg quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | N | a) Adjusted or matched for ANY confounders(other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | N
9236416 | Ross 1997 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | Y | a) Level of the exposure in comparative categories(eg quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | N | a) Adjusted or matched for ANY confounders(other than age and sex)? ** (y/n) | Y | b) Loss to follow-up<20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | ?
9236416 | Ross 1997 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | No data on tertile ranges. Unclear why some factors adjusted for and not others. Unclear if all stroke fatalities captured. No data on blinding.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Sambrook 2004, 2006

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
15531500 | Sambrook 2004 | Cohort study | ≥ 65 y; resides in nursing homes or hostels; ≥16 mo follow-up; available 25OH-D data | bedridden; bilateral amputees; non-English speaking; 1º hyperparathyroidism; severe renal impairment (serum Cr >300 μmol/L) | 1999 | Fracture Risk Epidemiology in the Elderly (FREE) | nd | SI
16598375 | Sambrook 2006 | Cohort study | All individuals from FREE study in whom serum samples were available for biochemical analysis | Patients with primary hyperparathyroidism were excluded from the analysis | June 1999 and Jan 2003 | Fracture Risk Epidemiology in the frail Elderly (FREE) Study | National Health and Medical Research Council of Australia and Arthritis Australia | MC

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or%body fat...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake...etc.)
15531500 | Sambrook 2004 | Cohort study | N. Sydney, Australia | 842 | 842 | 85 (nd) | nd | 22 | nd | 60 Kg | 7.2% DM; 62% HTN | nd
16598375 | Sambrook 2006 | Cohort study | North Sydney, Australia 33° 55’ South | 2005 (original cohort) | 1112 | 86.0 (6.9) | 65–104 (data for 2005 enrolled only) | 21.2 | nd | Mean weight: 59.6 kg | Mean number of medication:6.8 | “frail elderly”; 7.8% had hip fracture

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (e.g. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
15531500 16598375 | Sambrook 2004 Sambrook 2006 | 25(OH)D | | | | Diasorin radioimmunoassay kit (Stillwater, MN, US) | Intra-assay CV=7.6%;Inter-assay CV=9.0%. | nd | nd | Mean (SD) = 25 (18–37) nM vit D supplement (100–1000 IU daily) in 6.6% men; 10% women
| | Dietary calcium intake | nd | nd | | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
16598375 | Sambrook 2006 | Secondary (assumed because primary outcome of the original cohort was falls and fractures) | Total mortality | Mortality and cause of death were ascertained from death certificates and chart review during regular visits to institutions

UI | Author Year | Comments
15531500 | Sambrook 2004 | This paper described first 865 subjects who had completed at least 16 months follow-up from FREE study
16598375 | Sambrook 2006 | Backward elimination was used to select confounders to be included in the final multivariate regression analyses. 25(OH)D was not selected. Therefore, only results of univariate analysis were extracted here.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
15531500 | Sambrook 2004 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | No
15531500 | Sambrook 2004 | Demographics (e.g., age, gender, race, education)? | Yes age; gender
15531500 | Sambrook 2004 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no
15531500 | Sambrook 2004 | Medical conditions | illness severity
15531500 | Sambrook 2004 | Medication | no
15531500 | Sambrook 2004 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | no
15531500 | Sambrook 2004 | Smoking and other life styles variables | no
15531500 | Sambrook 2004 | Other | serum PTH, albumin, phosphate and calcium; bone U/S attenuation; Cr clearance

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
16598375 | Sambrook2006 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | | See above comments. Only results of univariate analysis were extracted here
16598375 | Sambrook2006 | Demographics (e.g., age, gender, race, education)? | no | See above comments. Only results of univariate analysis were extracted here
16598375 | Sambrook2006 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no | See above comments. Only results of univariate analysis were extracted here
16598375 | Sambrook2006 | Medical conditions | | See above comments. Only results of univariate analysis were extracted here
16598375 | Sambrook2006 | Medication | | See above comments. Only results of univariate analysis were extracted here
16598375 | Sambrook2006 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | | See above comments. Only results of univariate analysis were extracted here
16598375 | Sambrook2006 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no | See above comments. Only results of univariate analysis were extracted here
16598375 | Sambrook2006 | Other | | See above comments. Only results of univariate analysis were extracted here

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

MEAN DATA

THIS SHOULD ONLY APPLY TO CASE-COHORT STUDIES THAT COMPARE BASELINE VIT D/CA LEVELS BETWEEN CASES (WITH DISEASE) AND CONTROLS (WITHOUT DISEASE)

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Mean 25(OH)D Level | Vit D level CI/SE/SD* | Mean Ca intake or Ca balance | Ca CI/SE/SD* | P between groups
15531500 | Sambrook 2004 | Cases: 345 | 16–53 mo | adjusted for age and gender | 345 | 24.9 | 14.4 | | | 0.006
| | Control: 497 | 16–53 mo | adjusted for age and gender | 1112 | 27.9 | 15.7

Duplicate one table per outcome

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
15531500 | Sambrook2004 | Total mortality | After adjustment for age and gender, log 25OH-D was a significant predictor of mortality (HR 0.990 (0.982–0.998), P=0.001). In multivariate analysis that included serum PTH, 25OH-D and bone U/S attenuation, only PTH, Cr clearance, albumin, gender & illness severity remained significant predictors of mortality.
16598375 | Sambrook2006 | Total mortality | Over a median follow-up of 817 days (mean, 852 days; range: 4 2028 days), a total of 559 (50.3%) subjects died. Causes of death were cardiac (n=184), cerebrovascular (n=94), infections (mainly pneumonia; n=157), other (n=120: renal failure 19, cancer 24, respiratory 16, dementia 29, and others 32), and undetermined (n= 4). Eighty eight hip fractures occurred in 87 subjects during the period of follow-up. Result from univariate analysis for potential risk factors for total mortality: Using Log 25(OH)D as the independent variable, HR (95%CI) of total mortality was 0.87 (0.75–1.01), p=0.07 (n=1112)

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment* | | Biomarkers* | | Comparator | | Statistical Analysis | | Outcome | | Design
15531500 | Sambrook 2004 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | N | a) Method reported? (y/n) | Y | a) One of the prespecified methods*** was used? (y/n) | Y | a) Level of the exposure in comparative categories (e.g. quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | N | a) Adjusted or matched for ANY confounders (other than age and sex)?** (y/n) | Y | a) Clear definition of outcome, including time Y of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
15531500 | Sambrook 2004 | b) Sampling of population random N or consecutive? (y/n) | N | b) Outcome assessor blinded to exposure measurement? (y/n) | N | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | N | a) Level of the exposure in comparative categories (e.g. quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | N | a) Adjusted or matched for ANY confounders (other than age and sex)?** (y/n) | Y | b) Loss to follow-up N <20%? (y/n) | N | b) Analysis was planned when cohort was formed? (y/n) | nd
15531500 | Sambrook 2004 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | did not adjust for dietary factors, anthropometrics and additional variables relevant to vitamin D

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
16598375 | Sambrook 2006 | a) Eligibility criteria clear? (y/n) | N | a) Exposure assessor blinded to outcome info? (y/n) | Y | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | Y | a) Level of the exposure in comparative categories (e.g. quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | NA | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | N | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
16598375 | Sambrook 2006 | b) Sampling of population random or consecutive? (y/n) | N | b) Outcome assessor blinded to exposure measurement? (y/n) | N | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | N | a) Level of the exposure in comparative categories (e.g. quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | NA | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | N | b) Loss to follow-up <20%? (y/n) | N | b) Analysis was planned when cohort was formed? (y/n) | N
16598375 | Sambrook 2006 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Very selected subgroup of individuals from original cohort; 25(OH)D was not selected to enter final multivariate model. Therefore, only results of univariate analysis were used (no confounding was controlled).

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Schuurman 1999

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
10362125 | Schuurman 1999 | Case-cohort study | -male | -Hx of cancer (except skin cancer) -incomplete or inconsistent dietary data | 1986–1992 | Netherlands Cohort Study | Dutch Cancer Society | MB/SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
10362125 | Schuurman 1999 | Case- cohort study | Netherlands, 52.30 N | 2392 (original cohort size = 58279. 704 cases derived from entire cohort. Random subcohort sample of 1688 men used to estimate accumulated person years at risk) | 2167 (642 cases, 1525 controls) | Cases: 63.9±3.8 Controls: 61.4±4.2 | Range: 55–69 yrs | 100% | nd | nd | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
10362125 | Schuurman 1999 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | | | | nd
| | Dietary calcium intake | SFFQ (given at baseline to estimate consumption during the year preceding start of study) | Dutch food composition table | N | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
10362125 | Schuurman 1999 | nd | Prostate cancer | Computerized record linkage with all nine cancer registries in The Netherlands, and with the Dutch national data base of pathology reports

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
10362125 | Schuurman 1999 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes | Intake of Ca adjusted for energy. Total energy intake-adjusted. Mean intake of fresh meat, fish, cured meat, milk and milk products, cheese, eggs, calcium and protein did not differ among cases and subcohort members.
10362125 | Schuurman 1999 | Demographics (e.g., age, gender, race, education)? | Yes | Age-adjusted
10362125 | Schuurman 1999 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No
10362125 | Schuurman 1999 | Medical conditions | No
10362125 | Schuurman 1999 | Medication | No
10362125 | Schuurman 1999 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | No
10362125 | Schuurman 1999 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | No
10362125 | Schuurman 1999 | Other | Yes | Adjusted for family hx of prostate cancer and SES

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥ 2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outco me | Quintiles [Median Ca intake (mg/d)/cutpoint] | Mea n Vit D level/dose | Mea n Ca level/dose | No. of Cases (Event) * | Pers on- years | Mean Follow-up, mo | Crude or Adjusted analysis ? | Outcom e Metric (e.g. OR, RR, HR, %) | Outcom e effect size | CI | P betwe en group s *** | P for trend *** *
10362125 | Schuurman 1999 | Prostate cancer | 602/709 (reference group) | | | 120 | 1821 | 75 | Adjusted | RR | 1.0 | N/A
| | | 780/848 | | | 126 | 1845 | 75 | Adjusted | RR | 1.10 | 0.80–1.51 | >0.05
| | | 911/984 | | | 127 | 1840 | 75 | Adjusted | RR | 1.04 | 0.76–1.42 | >0.05
| | | 1064/1164 | | | 140 | 1817 | 75 | Adjusted | RR | 1.21 | 0.89–1.66 | >0.05
| | | 1329/nd | | | 129 | 1800 | 75 | Adjusted | RR | 1.09 | 0.79–1.50 | >0.05 | p=0.34

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
10362125 | Schuurman 1999 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | Y | a) Method reported? (y/n) | Y | a) One of the prespecifie d methods *** was used? (y/n) | NA | a) Level of the exposure in comparati ve categorie s (eg quartiles) N is given (ranges)? (y/n) applicabl e for categoric al analyses only | N | a) Adjusted or matched for ANY confounder s (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment ? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
10362125 | Schuurman 1999 | b) Sampling of population random or consecutive ? (y/n) | Y | b) Outcome assessor blinded to exposure measurement ? (y/n) | Y | b) Food compositio n database or suppl compositio n reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparati ve categorie s (eg quartiles) N is given (ranges)? (y/n) applicabl e for categoric al analyses only | N | a) Adjusted or matched for ANY confounder s (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
10362125 | Schuurman 1999 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justificatio n of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations) ? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Unclear the proportion of questionnaire validated against the 9-day diet record; accumulated person years at risk in the total cohort are estimated using a subcohort; no 1º outcome specified.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Scragg 1995

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
7498100 | Scragg 1995 | RCT | -Subjects recruited from general practitioner registers -63 – 76 yrs | -vit D medication/supplements -antihypertensive med | Dec. 1991 – Jan. 1992 | None | nd | MB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
7498100 | Scragg 1995 | RCT | Cambridge, UK 52°N | 191 | 189 | 69.6 (nd) | Age range: 63 – 76 yrs. | 46% | nd | Mean weight = 70.3 kg. Mean BMI = 25.8 | Healthy | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
7498100 | Scragg 1995 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | 25(OH)D competitive protein binding assay | Y, intra-assay coefficient of variation 2.7% | nd | | At baseline: Tx group mean = 13.8 ng/mL Control group mean = 12.9 ng/mL
7498100 | Scragg 1995 | Dietary calcium intake | nd | nd | nd | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
7498100 | Scragg 1995 | Cholecalciferol | Prepared in Arachis oil by a hospital and checked for bioactivity | 2.5 mg (100,000 IU) | Follow-up assessment 5 wks post drink | One time drink taken in presence of interviewer
7498100 | Scragg 1995 | Placebo | Prepared in Arachis oil by a hospital and checked for (lack of) bioactivity | | | One time drink taken in presence of interviewer
Co-intervention(s) * : | | | None
Compliance/Adherence: | | | nd

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
7498100 | Scragg 1995 | 1° | SBP | BP was measured twice pre and post intervention with a Hg sphygmomanometer and averaged
7498100 | Scragg 1995 | 1° | DBP | BP was measured twice pre and post intervention with a Hg sphygmomanometer and averaged
7498100 | Scragg 1995 | 2° | 25(OH)D | As measured by competitive protein binding assay

UI | Author Year | Comments
7498100 | Scragg 1995 | Complete trial performed during winter with goal of eliminating UV exposure as a confounder

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
7498100 | Scragg 1995 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
7498100 | Scragg 1995 | Demographics (e.g., age, gender, race, education)? | no | NS diff. in age between groups
7498100 | Scragg 1995 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no | NS diff. In BMI and body weight between groups
7498100 | Scragg 1995 | Medical conditions
7498100 | Scragg 1995 | Medication
7498100 | Scragg 1995 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location)
7498100 | Scragg 1995 | Smoking and other life styles variables | no | NS diff in % smokers between groups
7498100 | Scragg 1995 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline SD * | Delta ** | Delta SD * | Net difference | Net difference CI/SE/SD * | P between
7498100 | Scragg 1995 | SBP | mmHg | Vit D | 5 wks | 95 | 149 | 22 | −5 | 13 | 0 | | 0.81
7498100 | Scragg 1995 | SBP | mmHg | placebo | 5 wks | 94 | 147 | 23 | −5 | 16
| | DBP | | Vit D | 5 wks | 95 | 82 | 12 | −1 | 9 | 0 | | 0.92
| | DBP | | placebo | 5 wks | 94 | 82 | 10 | −1 | 9
| | 25(OH)D | ng/mL | Vit D | 5 wks | 95 | 13.8 | 5.9 | +7.2 | 3.8 | 8.6 | | 0.0001
| | 25(OH)D | ng/mL | placebo | 5 wks | 94 | 12.9 | 5.4 | −1.4 | 1.1

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “− “ sign: e.g. +2.8 or −2.8

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
7498100 | Scragg 1995 | RCT Parallel | Y | nd | NA | Y | Y | Y | Y | N | Y | A
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | possible confounders not accounted for

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Shin 2002

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
12208895 | Shin 2002 | Cohort study | Registered nurses from 11 states in the United Sates, women who completed the 1980 dietary questionnaire, did not have implausible values for total energy intake (<500 kcal or >3500kcal), had not left more than 10 food items blank, and had not been diagnosed with cancer by 1980 | nd | 1980 | Nurses’ Health Study | National cancer institute, national institutes of health, department of health and human services; American cancer society international union against cancer; and the Korean science and engineering foundation | JHL

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
12208895 | Shin 2002 | Cohort study | US | 88691 | 88381 | 46.7 (nd) | Nd | 0 | nd | Mean BMI at age 18y: 21.4, Mean height: 64.5 in. | History of osteoporosis: 1.2% Current smokers: 28.9% | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed information as possible on subject selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
12208895 | Shin 2002 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | nd | nd | nd | Total Vit D intake 306.7 IU/d
12208895 | Shin 2002 | Dietary calcium intake | (1980) 61 item FFQ, (1984, 1986, 1990, and 1994) approximately 130 foods - FFQ | USDA Nutrient data base | Y (see other article, Willett et al. 1988, Salvini et al. 1989) | | | | | Total Ca intake 773.7 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
12208895 | Shin 2002 | nd | Breast cancer | Medical records were obtained for breast cancer cases identified by either self-report or vital records, and more than 99% of these records confirmed the self-report.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
12208895 | Shin 2002 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Total energy intake, total fat intake, glycemic index, β-carotene intake, total active vit E intake, | For the analysis of postmenopausal women, age at menopause and postmenopausal hormone use were added.
12208895 | Shin 2002 | Demographics (e.g., age, gender, race, education)? | Yes - age, BMI at age 18 | For the analysis of postmenopausal women, age at menopause and postmenopausal hormone use were added.
12208895 | Shin 2002 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes - height, weight change since age 18, age at menarche, History of benign breast disease, family history of breast cancer, | For the analysis of postmenopausal women, age at menopause and postmenopausal hormone use were added.
12208895 | Shin 2002 | Medical conditions | | For the analysis of postmenopausal women, age at menopause and postmenopausal hormone use were added.
12208895 | Shin 2002 | Medication | | For the analysis of postmenopausal women, age at menopause and postmenopausal hormone use were added.
12208895 | Shin 2002 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | | For the analysis of postmenopausal women, age at menopause and postmenopausal hormone use were added.
12208895 | Shin 2002 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes - physical activity, alcohol intake, | For the analysis of postmenopausal women, age at menopause and postmenopausal hormone use were added.
12208895 | Shin 2002 | Other | Time period, parity, age at first birth | For the analysis of postmenopausal women, age at menopause and postmenopausal hormone use were added.

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥ 2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non- cases/Total N ** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
12208895 | Shin 2002 | Premenopausal women - Breast cancer | Total Ca group 1 | | ≤ 500 | 142 | | 192 | Adjusted | RR | 1.00 | | | 0.05
| | | Total Ca group 2 | | >500- ≤ 600 | 106 | | 192 | Adjusted | RR | 0.88 | 0.68– 1.13
| | | Total Ca group 3 | | >600- ≤ 700 | 133 | | 192 | Adjusted | RR | 0.97 | 0.76– 1.24
| | | Total Ca group 4 | | >700- ≤ 800 | 119 | | 192 | Adjusted | RR | 0.95 | 0.74– 1.22
| | | Total Ca group 5 | | >800- ≤ 1000 | 161 | | 192 | Adjusted | RR | 0.82 | 0.64– 1.05
| | | Total Ca group 6 | | >1000- ≤ 1250 | 104 | | 192 | Adjusted | RR | 0.75 | 0.57– 0.99
| | | Total Ca group 7 | | >1250 | 62 | | 192 | Adjusted | RR | 0.80 | 0.58– 1.12
12208895 | Shin 2002 | Postmenopausal women - Breast cancer | Total Ca group 1 | | ≤ 500 | 240 | | 192 | Adjusted | RR | 1.00 | | | 0.70
| | | Total Ca group 2 | | >500- ≤ 600 | 216 | | 192 | Adjusted | RR | 0.86 | 0.72– 1.04
| | | Total Ca group 3 | | >600- ≤ 700 | 293 | | 192 | Adjusted | RR | 0.94 | 0.79– 1.12
| | | Total Ca group 4 | | >700- ≤ 800 | 292 | | 192 | Adjusted | RR | 0.92 | 0.77– 1.10
| | | Total Ca group 5 | | >800- ≤ 1000 | 518 | | 192 | Adjusted | RR | 0.93 | 0.79– 1.10
| | | Total Ca group 6 | | >1000- ≤1250 | 433 | | 192 | Adjusted | RR | 0.90 | 0.76– 1.07
| | | Total Ca group 7 | | >1250 | 353 | | 192 | Adjusted | RR | 0.93 | 0.77– 1.12

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
12208895 | Shin 2002 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | nd | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | N | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
12208895 | Shin 2002 | b) Sampling of population random or consecutive? (y/n) | N | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | nd | b) Analysis was planned when cohort was formed? (y/n) | N
12208895 | Shin 2002 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Y | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | N | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Poor reporting

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Shin 2006

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17019716 | Shin 2006 | Cohort study | Women between the ages of 40 and 70 years were recruited in urban Shanghai | Subjects who had a previous history of cancer at baseline; those who reported an implausible total calorie intake (<500 or >3500 kcal/day); and those who moved away from Shanghai immediately after the baseline survey | March 1997 to May 2000 | Shanghai Women’s Health Study | NIH | AT

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
17019716 | Shin 2006 | Cohort study | urban Shanghai, China (31° 14′ N) | 73314 | 73314 | Cases: 59 (8.5); non- cases: 52 (9.1) | nd | 0 | Chinese | BMI, average (Kg/m ^ 2 ^ ): 24 Waist to hip ratio, average: 0.81 | Menopause: 49% CRC in first degree relatives: 2.2% Ever smoked regularly: 2.8% Ever drank alcohol regularly: 2.3% Ever exer cised r eg ular ly: 35% Ever used hormone replacement: 2% | Fruits/vegetables intake (g/d ay), average: 567.7 Meat intake (g/d ay), average: 50.1

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
17019716 | Shin 2006 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | na | na | na | na | na
17019716 | Shin 2006 | Dietary calcium intake | FFQ | The Chinese Food Composition Table was used to estimate the intake level of major nutrients for the study participants | y Intake levels of major nutrients and food obtained from the FFQ compared with those derived from multiple 24-hr dietary recalls. The correlation coefficients between FFQ and 24-hr dietary recalls were 0.54 for calcium | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17019716 | Shin 2006 | primary | Colorectal cancer | Cohort members have been followed by a combination of biennial follow-up surveys and record linkage to the Shanghai Cancer Registry and the Shanghai Vital Statistics Registry. The matching criteria used for linkage to identify cancer cases and deceased subjects in the cohort were citizen identification number, name, date of birth and address. International Classification of Diseases-9 (ICD-9) codes 153 and 154 were used to identify colon and rectal cancer cases, respectively. All possible matches were checked manually and verified through home visits.
| | secondary | Colon cancer
| | secondary | Rectal cancer

UI | Author Year | Comments
17019716 | Shin 2006 | Subjects were followed until diagnosis of cancer, death or June 30, 2004, whichever came first. If the subjects’ in-person contact occurred between June 30, 2004 and December 31, 2004, the date of contact was used as a last follow-up date. Mean values for the total sample were calculated by the mean values given for cases and non-cases respectively in the paper Median follow up: 5.75 years

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17019716 | Shin 2006 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes (vitamin supplement use and total energy intake)
17019716 | Shin 2006 | Demographics (e.g., age, gender, race, education)? | Yes (age at recruitment, education)
17019716 | Shin 2006 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No
17019716 | Shin 2006 | Medical conditions | Yes (menopausal status, family history of colorectal cancer among first degree relatives)
17019716 | Shin 2006 | Medication | No
17019716 | Shin 2006 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | No
17019716 | Shin 2006 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes (cigarette smoking, alcohol consumption, physically active during past 5 years)
17019716 | Shin 2006 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

All cases included (event = 283)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | No. of Non-cases/Total N** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI** | P between groups*** | P for trend****
17019716 | Shin 2006 | Colorectal cancer | 1 ^ st ^ quintile, median (mg/day) | | ≤ 291.9 | nd | nd | Median, 68.9 | adjusted | RR | 1.0 | | | 0.484
| | Colorectal cancer | 2 ^ nd ^ quintile, median (mg/day) | | ≤ 389.9 | nd | nd | Median, 68.9 | adjusted | RR | 1.0 | 0.7–1.4 | nd | 0.484
| | Colorectal cancer | 3 ^ rd ^ quintile, median (mg/day) | | ≤ 488.2 | nd | nd | Median, 68.9 | adjusted | RR | 1.0 | 0.7–1.4 | nd | 0.484
| | Colorectal cancer | 4 ^ th ^ quintile, median (mg/day) | | ≤ 610.8 | nd | nd | Median, 68.9 | adjusted | RR | 0.9 | 0.6–1.3 | nd | 0.484
| | Colorectal cancer | 5 ^ th ^ quintile, median (mg/day) | | > 610.8 | nd | nd | Median, 68.9 | adjusted | RR | 0.9 | 0.6–1.3 | nd | 0.484

Exclude first 2 years of follow-up (event = 220)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non-cases/Total N ** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups *** | P for trend ****
17019716 | Shin 2006 | Colorectal cancer | 1 ^ st ^ quintile, median (mg/day) | | ≤291.9 | nd | nd | nd | adjusted | RR | 1.0 | | | 0.023
| | Colorectal cancer | 2 ^ nd ^ quintile, median (mg/day) | | ≤389.9 | nd | nd | nd | adjusted | RR | 0.9 | 0.6–1.3 | nd | 0.023
| | Colorectal cancer | 3 ^ rd ^ quintile, median (mg/day) | | ≤488.2 | nd | nd | nd | adjusted | RR | 0.8 | 0.5–1.2 | nd | 0.023
| | Colorectal cancer | 4 ^ th ^ quintile, median (mg/day) | | ≤610.8 | nd | nd | nd | adjusted | RR | 0.7 | 0.4≤1.1 | nd | 0.023
| | Colorectal cancer | 5 ^ th ^ quintile, median (mg/day) | | > 610.8 | nd | nd | nd | adjusted | RR | 0.6 | 0.3–1.0 | nd | 0.023

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
17019716 | Shin 2006 | Additional analyses were performed after excluding the first year or first 2 years of follow-up periods to evaluate whether undiagnosed cancer cases at the baseline survey may affect the results. After excluding the first year of follow-up, higher intakes of calcium were associated with a decreased risk of colorectal cancer ( P for trend = 0.058, data not shown). In the subgroup analyses, similar associations were observed for colon and rectal cancer (data not shown). After excluding the first 2 years of follow-up, higher calcium intake significantly decreased the risk of colon cancer (p for trend = 0.030), but failed to reach any statistical significance for rectal cancer ( P for trend = 0.345).

Exclude first 2 years of follow-up (colon cancer, N = 129; rectal cancer, N = 91)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | No. of Non-cases/Total N** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI** | P between groups*** | P for trend****
17019716 | Shin 2006 | Colon cancer | 1 ^ st ^ quintile, median (mg/day) | | ≤ 291.9 | nd | nd | nd | adjusted | RR | 1.0 | | | 0.030
| | | 2 ^ nd ^ quintile, median (mg/day) | | ≤ 389.9 | nd | nd | nd | adjusted | RR | 1.0 | 0.6–1.0 | nd | 0.030
| | | 3 ^ rd ^ quintile, median (mg/day) | | ≤ 488.2 | nd | nd | nd | adjusted | RR | 0.6 | 0.4–1.1 | nd | 0.030
| | | 4 ^ th ^ quintile, median (mg/day) | | ≤ 610.8 | nd | nd | nd | adjusted | RR | 0.6 | 0.3–1.0 | nd | 0.030
| | | 5 ^ th ^ quintile, median (mg/day) | | > 610.8 | nd | nd | nd | adjusted | RR | 0.6 | 0.3–1.1 | nd | 0.030
| | Rectal cancer | 1 ^ st ^ quintile, median (mg/day) | | ≤ 291.9 | nd | nd | nd | adjusted | RR | 1.0 | | | 0.345
| | | 2 ^ nd ^ quintile, median (mg/day) | | ≤ 389.9 | nd | nd | nd | adjusted | RR | 0.8 | 0.4–1.5 | nd | 0.345
| | | 3 ^ rd ^ quintile, median (mg/day) | | ≤ 488.2 | nd | nd | nd | adjusted | RR | 1.2 | 0.6–2.1 | nd | 0.345
| | | 4 ^ th ^ quintile, median (mg/day) | | ≤ 610.8 | nd | nd | nd | adjusted | RR | 0.9 | 0.5–1.8 | nd | 0.345
| | | 5 ^ th ^ quintile, median (mg/day) | | > 610.8 | nd | nd | nd | adjusted | RR | 0.6 | 0.6–1.4 | nd | 0.345

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
17019716 | Shin 2006 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | N | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
17019716 | Shin 2006 | b) Sampling of population random or consecutive? (y/n) | N | b) Outcome assessor blinded to exposure measurement? (y/n) | N | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | Y
17019716 | Shin 2006 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Y | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Assessor blinding not reported; power calculation not reported; number of cases and non-cases per calcium quintile intake are not reported; confirmation of cases by histology not reported

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Skinner 2006

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
16985031 | Skinner 2006 | Cohort study | Nurses’ Healthy Study (NHS): initiated in 1976 when 121,701 US female registered nurses ages 30 to 55 years responded to a mailed questionnaire Health Professionals Follow-up (HPFS): began in 1986 when 51,529 US male health professionals ages 40 to 75 years responded to a mailed questionnaire | Prior cancers, except nonmelanoma skin cancer; missing dietary information | NHS: 1984 HPFS: 1986 | 1. NHS 2. HPFS | NIH and NHS’s grant | MC

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
16985031 | Skinner 2006 | Cohort study | Multiple cities in US | NHS: 121,701 HPFS: 51,529 | NHS: 75,427 HPFS: 46,771 | NHS: 51 (nd) HPFS: 55 (nd) | NHS: 30–55 HPFS: 40–75 | NHS: 0 HPFS: 100 | nd | Mean BMI - NHS: 24 HPFS: 25 | Diabetic – NHS: 3% HPFS: 1% | Residence in northern state– NHS: 50% HPFS: 74%

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
16985031 | Skinner 2006 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | | | | nd
16985031 | Skinner 2006 | Dietary calcium intake | FFQ (Willet, 1990) | Harvard University Food Composition Database, derived from USDA | Pearson r between FFQ and 4 1-week diet records for energy-adjusted calcium intake = 0.56 (HPFS cohort) | | | | | See results

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
16985031 | Skinner 2006 | nd | Pancreatic cancer | Self-reported diagnosis in the 2-year period before each questionnaire. Some permitted to confirm through medical records. Additionally, primary case of death by pancreatic cancer was used. Because no material differences were observed between these two types of cases, both cases with and without medical records were included in final analyses.

UI | Author Year | Comments
16985031 | Skinner 2006 | This article gave a pooled analysis of HPFS and NHS cohorts and separate data for each cohort. Only data from each cohort were extracted

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
16985031 | Skinner 2006 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Use of multivitamin supplement, dietary intake of vitamin D | Two statistical models: with and without adjustment for vitamin D were reported age
16985031 | Skinner 2006 | Demographics (e.g., age, gender, race, education)? | Yes
16985031 | Skinner 2006 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI, height
16985031 | Skinner 2006 | Medical conditions | History of DM
16985031 | Skinner 2006 | Medication
16985031 | Skinner 2006 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | Region of residence (south, north)
16985031 | Skinner 2006 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | smoking
16985031 | Skinner 2006 | Other | Parity (for women only)

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | Total N** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI** | P between groups*** | P for trend****
16985031 | Skinner 2006 | Pancreatic cancer | Total daily calcium intake (mg) in HPFS (men, 1986–2000) | | <500 | 17 | Person-year: 59,963 | Adjusted (but no dietary vitamin D) | RR | 1 | | | 0.19
| | | | | 500–999 | 119 | 372,213 | Adjusted (but no dietary vitamin D) | RR | 1.10 | 0.66–1.81
| | | | | ≥1000 | 51 | 179,381 | Adjusted (but no dietary vitamin D) | RR | 0.85 | 0.49–1.49
16985031 | Skinner 2006 | Pancreatic cancer | Total daily calcium intake (mg) in HPFS (men, 1986–2000) | | <500 | 17 | Person-year: 59,963 | Adjusted (including dietary vitamin D) | RR | 1 | | | 0.86
| | | | | 500–999 | 119 | 372,213 | Adjusted (including dietary vitamin D) | RR | 1.28 | 0.76–2.18
| | | | | ≥1000 | 51 | 179,381 | Adjusted (including dietary vitamin D) | RR | 1.23 | 0.67–2.25

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
16985031 | Skinner 2006 | Pancreatic cancer | Total daily calcium intake (mg) in NHS (women, 1984–2000) | | <500 | 24 | Person-year: 156,300 | Adjusted (but no dietary vitamin D) | RR | 1 | | | 0.04
| | | | | 500–999 | 109 | 665,099 | Adjusted (but no dietary vitamin D) | RR | 1.01 | 0.65–1.58
| | | | | ≥1000 | 45 | 340,595 | Adjusted (but no dietary vitamin D) | RR | 0.69 | 0.42–1.15
16985031 | Skinner 2006 | Pancreatic cancer | Total daily calcium intake (mg) in NHS (women, 1984–2000) | | <500 | 24 | Person-year: 156,300 | Adjusted (including dietary vitamin D) | RR | 1 | | | 0.09
| | | | | 500–999 | 109 | 665,099 | Adjusted (including dietary vitamin D) | RR | 1.09 | 0.69–1.73
| | | | | ≥1000 | 45 | 340,595 | Adjusted (including dietary vitamin D) | RR | 0.75 | 0.43–1.30

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
16985031 | Skinner 2006 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | Y | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories(eg quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders(other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
16985031 | Skinner 2006 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | N | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories(eg quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders(other than age and sex)? ** (y/n) | Y | b) Loss to follow-up<20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
16985031 | Skinner 2006 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Y | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | A
Explanation for Overall Quality Grade (if not Grade A):

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Slob 1993

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
8478144 | Slob 1993 | Cohort study | All civil servants in Amsterdam, aged between 40 and 65 years, and their spouses | Subjects without information on survival status or cause of death, with missing information on calcium intake and other potential confounding variables, with extremely low energy intake (i.e., for men <1500kcal, for women <1250kcal) | 1953–1954 | nd | nd | JHL

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location(e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean(SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
8478144 | Slob1993 | Cohort study | Amsterdam(52°18′ N) | 3091 | 2591 | Men 53(7.3) Women 52 (7.2) | 40–65y | 50.9% | nd | BMI Men 24.7 (2.7) Women 26.4 (3.7) | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
8478144 | Slob 1993 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | nd | nd | nd | nd
8478144 | Slob 1993 | Dietary calcium intake | FFQ (one-week recall) | Dutch food tables | n | | | | | Men 929±415mg/d Women 660±283mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
8478144 | Slob 1993 | nd | Gastrointestinal cancer mortality | The residence at death and the municipal death registration number were obtained from the Dutch Central Bureau of Genealogy. The combination of residence at death, date at death and municipal death registration number enabled linkage with the cause of death in the records of the Dutch Central Bureau of Statistics.
8478144 | Slob 1993 | nd | Cancer mortality | The residence at death and the municipal death registration number were obtained from the Dutch Central Bureau of Genealogy. The combination of residence at death, date at death and municipal death registration number enabled linkage with the cause of death in the records of the Dutch Central Bureau of Statistics.
8478144 | Slob 1993 | nd | All-cause mortality | The residence at death and the municipal death registration number were obtained from the Dutch Central Bureau of Genealogy. The combination of residence at death, date at death and municipal death registration number enabled linkage with the cause of death in the records of the Dutch Central Bureau of Statistics.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
8478144 | Slob 1993 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Energy intake, dietary fiber
8478144 | Slob 1993 | Demographics (e.g., age, gender, race, education)? | Yes - age
8478144 | Slob 1993 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no
8478144 | Slob 1993 | Medical conditions Medication Sunlight exposure and its proxy variables (e.g., seasonal variation of25(OH)D, UV exposure, location)
8478144 | Slob 1993 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) Other | no

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Followup Duration | Mean Ca level/dose | No. of Cases (Event) | Total N ** | Crude or Adjusted analysis? | Outcome Metric(e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
8478144 | Slob 1993 | All cause mortality – Men | Ca quintile 1 | 28 yr | ≤585 | nd | nd | Adjusted | OR | 1.1 | 0.7–1.6 | nd | nd
| | | Ca quintile 2 | | 585<≤725 | nd | nd | Adjusted | OR | 1.1 | 0.7–1.6 | nd | nd
| | | Ca quintile 3 | | 725<≤935 | nd | nd | Adjusted | OR | 0.8 | 0.5–1.2 | nd | nd
| | | Ca quintile 4 | | 935<≤1245 | nd | nd | Adjusted | OR | 0.9 | 0.6–1.3 | nd | nd
| | | Ca quintile 5 | | >1245 | nd | nd | Adjusted | OR | 1.0 | | nd | nd
8478144 | Slob 1993 | Total cancer mortality – Men | Ca quintile 1 | 28 yr | ≤585 | 232 (total cases) | 1321 (total) | Adjusted | OR | 1.0 | 0.6–1.6 | nd | nd
| | | Ca quintile 2 | | 585<,≤725 | nd | nd | Adjusted | OR | 1.0 | 0.6–1.6 | nd | nd
| | | Ca quintile 3 | | 725<,≤935 | nd | nd | Adjusted | OR | 1.0 | 0.6–1.5 | nd | nd
| | | Ca quintile 4 | | 935<, ≤1245 | nd | nd | Adjusted | OR | 0.8 | 0.5–1.3 | nd | nd
| | | Ca quintile 5 | | >1245 | nd | nd | Adjusted | OR | 1.0 | | nd | nd
8478144 | Slob 1993 | Gastrointestinal cancer mortality – Men | Ca quintile 1 | 28 yr | ≤585 | nd | nd | Adjusted | OR | 1.5 | 0.7–3.2 | nd | nd
| | | Ca quintile 2 | | 585<,≤725 | nd | nd | Adjusted | OR | 1.1 | 0.5–2.3 | nd | nd
| | | Ca quintile 3 | | 725<, ≤935 | nd | nd | Adjusted | OR | 1.1 | 0.5–2.2 | nd | nd
| | | Ca quintile 4 | | 935<,≤1245 | nd | nd | Adjusted | OR | 0.6 | 0.3–1.4 | nd | nd
| | | Ca quintile 5 | | >1245 | nd | nd | Adjusted | OR | 1.0 | | nd | nd
8478144 | Slob 1993 | All cause mortality – Women | Ca quintile 1 | 28 yr | ≤445 | nd | nd | Adjusted | OR | 1.2 | 0.8–1.9 | nd | nd
| | | Ca quintile 2 | | 445<, ≤ 540 | nd | nd | Adjusted | OR | 1.1 | 0.7–1.7 | nd | nd
| | | Ca quintile 3 | | 540<,≤640 | nd | nd | Adjusted | OR | 1.3 | 0.9–2.0 | nd | nd
| | | Ca quintile 4 | | 640<, ≤850 | nd | nd | Adjusted | OR | 1.1 | 0.7–1.7 | nd | nd
| | | Ca quintile 5 | | >850 | nd | nd | Adjusted | OR | 1.0 | | nd | nd
8478144 | Slob 1993 | Total cancer mortality – Women | Ca quintile 1 | 28 yr | ≤445 | 127 (total cases) | 1270 (total) | Adjusted | OR | 1.1 | 0.6–2.1 | nd | nd
| | | Ca quintile 2 | | 445<,≤540 | nd | nd | Adjusted | OR | 0.8 | 0.4–1.5 | nd | nd
| | | Ca quintile 3 | | 540<,≤640 | nd | nd | Adjusted | OR | 1.6 | 0.9–2.8 | nd | nd
| | | Ca quintile 4 | | 640<,≤850 | nd | nd | Adjusted | OR | 1.4 | 0.7–2.5 | nd | nd
| | | Ca quintile 5 | | >850 | nd | nd | Adjusted | OR | 1.0 | | nd | nd
8478144 | Slob 1993 | Gastrointestinal cancer mortality – Women | Ca quintile 1 | 28 yr | ≤445 | nd | nd | Adjusted | OR | 3.1 | 0.8–12.3 | nd | nd
| | | Ca quintile 2 | | 445<,≤540 | nd | nd | Adjusted | OR | 1.6 | 0.4–7.2 | nd | nd
| | | Ca quintile 3 | | 540<,≤640 | nd | nd | Adjusted | OR | 3.8 | 1.0–13.9 | nd | nd
| | | Ca quintile 4 | | 640<,≤ 850 | nd | nd | Adjusted | OR | 1.8 | 0.4–7.7 | nd | nd
| | | Ca quintile 5 | | >850 | nd | nd | Adjusted | OR | 1.0 | | nd | nd

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
8478144 | Slob 1993 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | Y | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | N | a) Level of the exposure in comparative categories (eg quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
8478144 | Slob 1993 | b) Sampling of population random or consecutive? (y/n) | N | b) Outcome assessor blinded to exposure measurement? (y/n) | Y | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | N | a) Level of the exposure in comparative categories (eg quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up<20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
8478144 | Slob 1993 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | N | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | No internal calibration of dietary assessment (FFQ). No data on number of cases per calcium intake category.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Sneve 2008

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
19056900 | Sneve 2008 | RCT | -men and women −21–70 yrs old -BMI between 28.0 and 47.0 kg/m ^ 2 ^ | - diabetes, hx of MI, angina pectoris, stroke, renal stone disease, sarcoidosis -wt loss of more than 10% of total body wt during the last 6 mos., those using antidepressant drugs or wt reducing drugs, participation in an organized wt loss program, pregnant or lactating women, women planning to become pregnant in the next 12 mos., women below the age of 50 yrs without adequate contraception, subjects with serum Ca > 2.55 mmol/L, males with serum creatinine > 129 micromol/L, and females with serum creatinine > 104 micromol/L | 2005–2007 | nd | The Northern Norway Regional Health Authority | MB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
19056900 | Sneve 2008 | RCT | North Norway (latitude = 70 N) | 445 | 334 | 47.6 (11.4) | nd | 36% | nd | Weight(kg)=100.1 (14.2) BMI=34.8(3.9) % body fat=43.0 (7.5) waist hip ratio=0.97 (0.09) | Overweight or obese, 22% smokers | Serum Ca(mmol/L)=2.31(0.11) Serum 25(OH)D (nmol/L)=53.1(16.9) Calorie intake (J/day)=9161(2887) Ca intake (mg/day)=940(398) Vit D intake (mcg/day)=8.9(6.6)

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed information as possible on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
19056900 | Sneve 2008 | 25(OH)D | | | | electrochemiluminescence | Yes: according to producer, the assay has, for total analytical precison, a coeff of variation ≤7.8% as judged in any of three different concentrations (48.6 – 73.8 – 177.0 nmol/L) | nd | nd | Vit D intake (mcg/day)=8.9(6.6) Serum 25(OH)D (nmol/L)=53.1(16.9)
| | Dietary calcium intake | FFQ | nd | nd | Serum Ca was measured at baseline and at 3, 6, 9, and 12 months. Urine for measurement of Ca excretion was collected for 24 hr at baseline and at the end of the study. | nd | | nd | Ca intake (mg/day)=940(398) Serum Ca(mmol/L)=2.31(0.11)

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
19056900 | Sneve 2008 | Vit D + Ca | Vit D capsules from Jenapharm, Jena, Germany. Ca supplement – Nycoplus Ca, Nycomed, Oslo, Norway) | 5714 IU cholecalciferol + 500 mg Ca | 1 yr | 2 capsules each containing 20,000 IU cholecalciferol taken twice a week (Monday and Thursday). Ca supplement taken daily
| | Vit D + Ca + placebo | Vit D capsules from Jenapharm, Jena, Germany. Ca supplement – Nycoplus Ca, Nycomed, Oslo, Norway). Placebo capsules, purchased from Hasco-lek, Wroclaw, Poland, were identical to the vit D capsules | 2857 IU cholecalciferol + 500 mg Ca | 1 yr | 1 capsule containing 20,000 IU cholecalciferol taken once a week (Monday or Thursday). One placebo capsule taken each week (Monday or Thursday). Ca supplement taken daily.
| | Ca + placebo | Ca supplement – Nycoplus Ca, Nycomed, Oslo, Norway. Placebo capsules, purchased from Hasco-lek, Wroclaw, Poland, were identical to the vit D capsules | 500 mg Ca | 1 yr | 2 placebo capsules taken each week (Monday and Thursday). Ca supplement taken daily.
Co-intervention(s) * : | | | At the baseline visit, any supplements with Ca and vit D were discontinued. Participants were given written recommendations on healthy diet and physical activity.
Compliance/Adherence: | | | If participant missed a capsule on assigned day, it could be taken another day. If a whole week was missed, double dose could be taken the next week. The compliance rate for cholecalciferol/placebo capsules were 95% in all 3 groups, and for the calcium tablets 81, 85, and 83% in the vitD+Ca, vitD+Ca+placebo, and Ca+placebo groups respectively.

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
19056900 | Sneve 2008 | 1° | weight
| | 2° | BMI
| | 2° | Serum 25(OH)D

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
19056900 | Sneve 2008 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes – 3 groups matched on vit D intake, Ca intake, calorie intake
19056900 | Sneve 2008 | Demographics (e.g., age, gender, race, education)? | Yes – 3 groups matched on age, adjusted for sex
19056900 | Sneve 2008 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes – 3 groups matched on BMI, body weight, % body fat, and waist hip ratio
19056900 | Sneve 2008 | Medical conditions Medication Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) Other | Yes – 3 groups matched on % smokers and physical activity score

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP) (SEE COMMENTS FOR RESULTS SECTION BELOW)

UI | Author Year | Outcome | Unit | Exposure Category/Intervention Group | Crude or Adjusted analysis? | Mean Follow-up (months) | No. Analyzed | Baseline | Baseline SD * | Delta ** | Delta SD * | Net difference *** | Net difference CI/SE/SD * | P between groups ***
19056900 | Sneve 2008 | weight | kg | Vit D + Ca | crude | 12 | 116 | 101 | 14.5 | +0.1 | 3.8 | vs. Ca+placebo group = −0.4 | | NS
| | | | Vit D + Ca + placebo | crude | 12 | 106 | 98.6 | 14.3 | +0.3 | 3.2 | vs. Ca+placebo group = −0.2 | | NS
| | | | Ca + placebo | crude | 12 | 112 | 100.6 | 13.9 | +0.5 | 3.9 | | | NS
19056900 | Sneve 2008 | BMI | Kg/m ^ 2 ^ | Vit D + Ca | crude | 12 | 116 | 35.0 | 4.1 | 0.0 | 1.3 | vs. Ca+placebo group = −0.2 | | NS
| | | | Vit D + Ca + placebo | crude | 12 | 106 | 34.4 | 3.9 | +0.1 | 1.1 | vs. Ca+placebo group = −0. 1 | | NS
| | | | Ca + placebo | crude | 12 | 112 | 35.1 | 3.8 | +0.2 | 1.4 | | | NS
19056900 | Sneve 2008 | Serum 25(OH)D | nmol/L | Vit D + Ca | crude | 12 | 116 | 54.5 | 16.7 | +59.8 | 21.1 | vs. Ca+placebo group = +62.1 | | P<0.05 versus Ca+placebo group
| | | | Vit D + Ca + placebo | crude | 12 | 106 | 51.4 | 18.4 | +37.8 | 15.7 | vs. Ca+placebo group = +40.1 | | P<0.05 versus Ca+placebo group
| | | | Ca + placebo | crude | 12 | 112 | 53.2 | 15.4 | −2.3 | 9.5 | | | NS

Duplicate one row per exposure category or intervention group. Please write “nd” if there was no data reported. DO NOT LEAVE BLANK.

* Please choose one and delete the others

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
19056900 | Sneve 2008 | In results above, baseline values are for all 445 subjects randomized but the delta values are for the 334 subjects who completed the study.

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis(y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
19056900 | Sneve 2008 | RCT -parallel | nd | Y | NA | N | nd | Y | Y | Y | Y | B
Adverse Event(s): ** | | | | | | 2 subjects were diagnosed with 1° hyperparathyroidism during the study and 1 subject had an increase in serum Ca to 2.62 mmol/L. All 3 subjects were excluded from the study. 4 subjects had transient increases in serum Ca > 2.59 mmol/L and remained in the study. 317 other adverse events were recorded, most of them related to GI discomfort. There were no significant differences between the treatment groups regarding adverse events.
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Dropout rate greater than 20%. No explanation for high non-completion rate. Randomization technique not described.

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse events.

## Stemmermann 1990

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
2311461 | Stemmermann 1990 | Cohort study | Men of Japanese ancestry born in the years 1900 through 1919 and living on the Hawaiian island of Oahu in 1965 | Men excluded because of prevalent colorectal cancer; or because the subject considered his intake in the previous 24 hours to be atypical | 1965 – 1968 | Japan Hawaii Cancer Study | NCI | AT

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
2311461 | Stemmermann 1990 | Cohort study | Hawaiian island of Oahu (21° 19’N) | 8006 | 8006 | nd | nd | 100 | Japanese | nd | nd | Average calcium intake (mg/day): 503.23 Average fat intake (g/day): 85.58

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
2311461 | Stemmermann 1990 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | na | na | na | na | na
2311461 | Stemmermann 1990 | Dietary calcium intake | 24h diet recall interview was administered to each subject by dieticians; food models and serving utensils were used to illustrate portion sizes | y Food composition tables were compiled from the best available sources to calculate individual intakes of nutrients | nd | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
2311461 | Stemmermann 1990 | primary | Colon cancer | Ascertainment of incident cancers was conducted by a periodic review of hospital discharge records for the island of Oahu. A computerized record linkage was performed between the study file and files of the Hawaii Tumor Registry to reduce the possibility of missing incidence cases. Each case of carcinoma was confirmed by histologic examination. The number of cancer cases identified by subsites of the large bowel were as follows: cecum and ascending colon (ICD-8: 153.0); transverse (ICD-8: 153.1) and descending colon (ICD-8: 153.2); sigmoid colon (ICD-8: 153.3); rectosigmoid (ICD-8: 154.0); and rectal (ICD-8: 154.1)
| | primary | Cecum/ascending colon cancer
| | primary | Transverse/descending colon cancer
| | primary | Sigmoid colon cancer
| | primary | Rectal cancer
| | primary | Rectosigmoid cancer
| | primary | Rectum cancer
| | secondary | Large bowel cancer

UI | Author Year | Comments
2311461 | Stemmermann 1990 | max follow up: 22 years

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
2311461 | Stemmermann 1990 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | No
2311461 | Stemmermann 1990 | Demographics (e.g., age, gender, race, education)? | Yes (age)
2311461 | Stemmermann 1990 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No
2311461 | Stemmermann 1990 | Medical conditions | No
2311461 | Stemmermann 1990 | Medication | No
2311461 | Stemmermann 1990 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | No
2311461 | Stemmermann 1990 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | No
2311461 | Stemmermann 1990 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non-cases N ** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups *** | P for trend ****
2311461 | Stemmermann 1990 | All colon tumors | High tertile | | nd | 58 | 2403 | nd | adjusted | RR | 1.0 | | | 0.16
| | All colon tumors | Medium tertile | | nd | 57 | 2399 | nd | adjusted | RR | 1.0 | 0.7–1.4 | nd | 0.16
| | All colon tumors | Low tertile | | nd | 74 | 2392 | nd | adjusted | RR | 1.3 | 0.9–1.8 | nd | 0.16
| | Cecum/ascending colon cancer | High tertile | | nd | 16 | 2403 | nd | adjusted | RR | 1.0 | | | 0.76
| | Cecum/ascending colon cancer | Medium tertile | | nd | 9 | 2400 | nd | adjusted | RR | 0.6 | 0.2–1.3 | nd | 0.76
| | Cecum/ascending colon cancer | Low tertile | | nd | 18 | 2392 | nd | adjusted | RR | 1.0 | 0.6–2.2 | nd | 0.76
| | Transverse/descending colon cancer | High tertile | | nd | 14 | 2403 | nd | adjusted | RR | 1.0 | | | 0.20
| | Transverse/descending colon cancer | Medium tertile | | nd | 11 | 2399 | nd | adjusted | RR | 0.8 | 0.4–1.7 | nd | 0.20
| | Transverse/descending colon cancer | Low tertile | | nd | 8 | 2392 | nd | adjusted | RR | 0.6 | 0.2–1.3 | nd | 0.20
| | Sigmoid colon cancer | High tertile | | nd | 28 | 2403 | nd | adjusted | RR | 1.0 | | | 0.02
| | Sigmoid colon cancer | Medium tertile | | nd | 37 | 2399 | nd | adjusted | RR | 1.3 | 0.8–2.2 | nd | 0.02
| | Sigmoid colon cancer | Low tertile | | nd | 48 | 2392 | nd | adjusted | RR | 1.7 | 1.1–2.8 | nd | 0.02

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

MEAN DATA

THIS SHOULD ONLY APPLY TO CASE-COHORT STUDIES THAT COMPARE BASELINE VIT D/CA LEVELS BETWEEN CASES (WITH DISEASE) AND CONTROLS (WITHOUT DISEASE) NOTE: for this specific study (cohort study) this type of analysis may be considered inappropriate

Colon cancer

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Mean 25(OH)D Level | Vit D level CI/SE/SD* | Mean Ca intake or Ca balance | Ca SE* | P between groups
2311461 | Stemmermann 1990 | Cases: 189 | nd | adjusted | 189 | | | 481.50 | 21.97 | ns
| | Control: 7195 | nd | adjusted | 7195 | | | 502.76 | 3.56 | ns

Duplicate one table per outcome

Cecum/ascending colon cancer

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Mean 25(OH)D Level | Vit D level CI/SE/SD* | Mean Ca intake or Ca balance | Ca SE* | P between groups
2311461 | Stemmermann 1990 | Cases: 43 | nd | adjusted | 43 | | | 518.90 | 46.05 | ns
| | Control: 7195 | nd | adjusted | 7195 | | | 502.76 | 3.56 | ns

Transverse/descending colon cancer

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Mean 25(OH)D Level | Vit D level CI/SE/SD* | Mean Ca intake or Ca balance | Ca SE* | P between groups
2311461 | Stemmermann 1990 | Cases: 33 | nd | adjusted | 33 | | | 551.55 | 52.56 | ns
| | Control: 7195 | nd | adjusted | 7195 | | | 502.76 | 3.56 | ns

Sigmoid colon cancer

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Mean 25(OH)D Level | Vit D level CI/SE/SD* | Mean Ca intake or Ca balance | Ca SE* | P between groups
2311461 | Stemmermann 1990 | Cases: 113 | nd | adjusted | 113 | | | 446.86 | 28.40 | 0.05
| | Control: 7195 | nd | adjusted | 7195 | | | 502.76 | 3.56 | 0.05

Rectal cancer

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Mean 25(OH)D Level | Vit D level CI/SE/SD* | Mean Ca intake or Ca balance | Ca SE* | P between groups
2311461 | Stemmermann 1990 | Cases: 88 | nd | adjusted | 88 | | | 524.48 | 32.21 | ns
| | Control: 7195 | nd | adjusted | 7195 | | | 502.76 | 3.56 | ns

Rectosigmoid cancer

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Mean 25(OH)D Level | Vit D level CI/SE/SD* | Mean Ca intake or Ca balance | Ca SE* | P between groups
2311461 | Stemmermann 1990 | Cases: 39 | nd | adjusted | 39 | | | 495.23 | 48.34 | ns
| | Control: 7195 | nd | adjusted | 7195 | | | 502.76 | 3.56 | ns

Rectum cancer

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Mean 25(OH)D Level | Vit D level CI/SE/SD* | Mean Ca intake or Ca balance | Ca SE* | P between groups
2311461 | Stemmermann 1990 | Cases: 49 | nd | adjusted | 49 | | | 547.87 | 43.16 | ns
| | Control: 7195 | nd | adjusted | 7195 | | | 502.76 | 3.56 | ns

Large bowel cancer

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Mean 25(OH)D Level | Vit D level CI/SE/SD* | Mean Ca intake or Ca balance | Ca SE* | P between groups
2311461 | Stemmermann 1990 | Cases: 277 | nd | adjusted | 277 | | | 495.14 | 18.16 | ns
| | Control: 7195 | nd | adjusted | 7195 | | | 502.76 | 3.56 | ns

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
2311461 | Stemmermann 1990 | Besides total calcium intake, results were also given as subgroup analyses for dairy calcium intake and non-dairy calcium intake Rectosigmoid and rectum cancer were not associated with calcium intake (data not shown)

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
2311461 | Stemmermann 1990 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | N | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | N | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
2311461 | Stemmermann 1990 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to N exposure measurement? (y/n) | N | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | N | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | Y
2311461 | Stemmermann 1990 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | NA | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Study designed to compare cancer events in large bowel subsites between group with dairy calcium intake and group with non-dairy calcium intake; assessor blinding not reported; confounding factors not included in the analyses; power calculations not reported; results are not reported for all the outcomes (large bowel cancer per subsite); use of 24h recall interview instead of FFQ

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Stolzenberg 2009

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
19208842 | Stolzenberg, 2009 | Case- cohort study | Men and women, aged 55 to 74 y, from the Prostate, Lung, ovarian, and Colorectal Cancer Screening Trial (PLCO). Cases: All incident cases of pancreatic adenocarcinomas occurred between 1994 and 2006 (follow-up to 11.7 y; median, 5.4 y) Controls: selected from all PLCO study participants with serum samples and who were alive at the time the case was diagnosed. Two controls were matched to each case by age (±5 y), race, sex, and calendar date of blood draw in 2-mo blocks. | A personal history of one of the 4 PLCO cancers or those currently undergoing treatment for any cancer, except nonmelanoma of the skin, as well as subjects who had been screened fro prostate or colorectal cancer during the prior 3 y | November 1993 – July 2001 | PLCO | NIH | MC

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
19208842 | Stolzenberg, 2009 | Case- cohort study | Multicenters in the US: Birmingham, AL; Denver, CO; Detroit, MI; Honolulu, HI; Marshfield, WI; Minneapolis, MN; Pittsburgh, PA; Salt lake City, UT; St. Louis MO; and Washington, DC) | Original RCT participants: 152,810 Cases: 184 Controls: 368 | Cases: 184 Controls: 368 | Cases: 66 Controls: 66 | Cases: IQR 59– 72 Controls: IQR 58– 72 | 65.2 | 90.2% White, 3.3% Black, 1.6% Hispanic, 4.9% Asian | Mean (IQR) BMI – Cases: 26.7 (22.3–32.7) Controls: 26.3 (22.0–33.0) | DM: 10.5% Gallbladder disease: 13.2% | Vit D inadequacy (<40 nol/L): 14%

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed information as possible on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
19208842 | Stolzenberg, 2009 | 25(OH)D | | | | RIA (Heartland Assays lab) | Yes Overall CV = 4.7% | Within 2 hr | calendar date of blood draw in 2-mo blocks was matching factor to control for seasonal variation in the analysis | Residential sum exposure at study entry- Low sun: 47% Moderate sun 45% High sun: 8%
19208842 | Stolzenberg, 2009 | Dietary calcium intake | 137 item FFQ (Deeb, 2007) | nd | nd | N/A | | | | Median (IQR) total calcium intake – Cases: 1091 (710–1942) mg/d Controls: 1133 (732–1776) mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
19208842 | Stolzenberg, 2009 | | Pancreatic cancer | Vital status of cohort participants and pancreatic cancer cases was identified by self-report survey, state cancer registries, death certificates, physician referrals, and reports from next of kin for deceased individuals. Medical and pathologic records related to pancreatic cancer diagnosis and supporting doc were obtained. 90.2% of pancreatic cancer cases were confirmed through medical review.

UI | Author Year | Comments
19208842 | Stolzenberg, 2009 | 2.5% had family history of pancreatic cancer. No differences between cases and controls.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
19208842 | Stolzenberg, 2009 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
19208842 | Stolzenberg, 2009 | Demographics (e.g., age, gender, race, education)? | Yes *
19208842 | Stolzenberg, 2009 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes * | BMI
19208842 | Stolzenberg, 2009 | Medical conditions
19208842 | Stolzenberg, 2009 | Medication
19208842 | Stolzenberg, 2009 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | Seasonal variation of 25(OH)D, and residential sun exposure (low, moderate or high) | Seasonal variation of 25(OH)D was one of the matching factor; residential sun exposure was treated as effect modifier (stratified analyses) smoking
19208842 | Stolzenberg, 2009 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes *
19208842 | Stolzenberg, 2009 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥ 2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non- cases ** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups *** | P for trend ****
19208842 | Stolzenberg, 2009 | Pancreatic cancer | 25(OH)D quintiles, nmol/L | ≤ 45.9 | | 44 | 74 | Median 5.4 y (up to 11.7 y) | Adjusted | OR | 1 (ref) | | nd
| | | | >45.9 and ≤ 60.3 | | 40 | 74 | | | | 0.97 | 0.47– 1.98 | | 0.49
| | | | >60.3 and ≤ 69.5 | | 27 | 73 | | | | 0.86 | 0.40– 1.84
| | | | >69.5 and ≤ 82.3 | | 31 | 74 | | | | 0.84 | 0.39–1.80
| | | | >82.3 | | 42 | 73 | | | | 1.45 | 0.66– 3.15

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
19208842 | Stolzenberg, 2009 | Pancreatic cancer | | | 25(OH)D, nmol/L (quartile) | | | | P interaction
19208842 | Stolzenberg, 2009 | Pancreatic cancer | | | <49.3 | >49.3 and <65.2 | >65.2 and <78.4 | >78.4
19208842 | Stolzenberg, 2009 | Pancreatic cancer
19208842 | Stolzenberg, 2009 | Pancreatic cancer | Residential sum exposure, low* | Case/control, n (91/167) | 22/44 | 22/42 | 21/43 | 26/38
19208842 | Stolzenberg, 2009 | Pancreatic cancer | Residential sum exposure, low* | Adj OR (95% CI) | 1 (ref) | 2.52 (0.92– 6.90) | 2.33 (0.83– 6.48) | 4.03 (1.38– 11.79) | 0.015
19208842 | Stolzenberg, 2009 | Pancreatic cancer
19208842 | Stolzenberg, 2009 | Pancreatic cancer | Residential sum exposure, moderate/high* | Case/control, n (93/201) | 33/48 | 15/50 | 18/49 | 24/54
19208842 | Stolzenberg, 2009 | Pancreatic cancer | Residential sum exposure, moderate/high* | Adj OR (95% CI) | 1.97 (0.80– 4.82) | 0.66 (0.22– 2.01) | 0.91 (0.31–2.71) | 1.45 (0.53–3.96)
19208842 | Stolzenberg, 2009 | Pancreatic cancer
19208842 | Stolzenberg, 2009 | Pancreatic cancer | *Residential regions based on ranges of UV radiation levels obtained from annual R-B meter in states in which screening centers are located: low sun (R-B 105, Detroit, MI; Minneapolis, MN; Marshfield, WI), moderate/high sun (R-B=113–134, Pittsburgh, PA; St. Louis, MO; Denver, CO; Washington, DC; Salt Lake City, UT, and R-B 154, Brimingham, AL; Honolulu, HI)
19208842 | Stolzenberg, 2009 | Pancreatic cancer | The adjusted Ors for each respective quartile compared with the first after the exclusion of the cases that occurred during the first 2 years (n=153 cases in analysis) were 0.78, 0.98 and 1.47 (95%Ci, 0.70–2.99, p trend=0.3) and 5 years (n=105 cases in analysis) were 0.52, 1.27 and 2.21 (95% CI, 0.92–5.30; p trend-0.06)

UI | Author Year | Comments for Results
19208842 | Stolzenberg, 2009 | There was no significant interaction of 25(OH)D status and pancreatic cancer by smoker status, sex, physical activity, or total vitamin A intake.

Blood drawn in fall and winter season

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | No. of Non- cases** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups*** | P for trend****
19208842 | Stolzenberg, 2009 | Pancreatic cancer | 25(OH)D quintiles, nmol/L | ≤ 45.9 | | 25 | 50 | Median 5.4 y (up to 11.7 y) | Adjusted | OR | 1 (ref) | | nd | 0.10
| | | | >45.9 and ≤ 60.3 | | 15 | 37 | | | | 1.95 | 0.72–5.27
| | | | >60.3 and ≤ 69.5 | | 10 | 26 | | | | 1.82 | 0.56–5.96
| | | | >69.5 and | | 13 | 29 | | | | 1.06 | 0.35–3.27
| | | | ≤82.3
| | | | >82.3 | | 14 | 12 | | | | 3.91 | 1.19–12.85

Blood drawn in spring and summer season

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | No. of Non-cases** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups*** | P for trend****
19208842 | Stolzenberg, 2009 | Pancreatic cancer | 25(OH)D quintiles, nmol/L | ≤45.9 | | 19 | 24 | Median 5.4 y (up to 11.7 y) | Adjusted | OR | 1 (ref) | | nd | 0.55
| | | | >45.9 and ≤60.3 | | 25 | 37 | | | | 0.39 | 0.13–1.23
| | | | >60.3 and ≤69.5 | | 17 | 47 | | | | 0.38 | 0.13–1.14
| | | | >69.5 and ≤82.3 | | 18 | 45 | | | | 0.44 | 0.14–1.35
| | | | >82.3 | | 28 | 61 | | | | 0.59 | 0.20–1.75

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
19208842 | Stolzenberg, 2009 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | Y | a) Method reported? (y/n) | y | a) One of the prespecified methods *** was used? (y/n) | y | a) Level of the exposure in comparative categories(eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders(other than age and sex)? ** (y/n) | y | a) Clear definition of outcome, including time of ascertainment? (y/n) | y | a) Prospective collection of data? (y/n) | y
19208842 | Stolzenberg, 2009 | b) Sampling of population random or consecutive? (y/n) | n | b) Outcome assessor blinded to exposure measurement? (y/n) | y | b) Food composition database or suppl composition reported? (y/n) | n | Time from sample collection to sample analysis reported? (y/n) | y | a) Level of the exposure in comparative categories(eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders(other than age and sex)? ** (y/n) | y | b) Loss to follow-up<20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | n
19208842 | Stolzenberg, 2009 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | n | | | | | b) Justification of final adjusted model selection? (y/n) | y | c) Do the authors specify a primary outcome? (y/n) | n | c) Justification of sample size (includes sample size calculations)? (y/n) | n
OVERALL Grade (A/B/C): | | | | | | | A
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Small number of cases in some subgroup analyses; analyses were not planned when trial was formed.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Stolzenberg-Solomon 2006

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17047087 | Stolzenberg-Solomon 2006 | Case-cohort study | All cases of pancreatic cancer diagnosed between January 1985 and December 2001 were identified through the Finnish Cancer Registry among 29,133 eligible men in south western Finland, ages 50 to 69 years, who smoked at least 5 cigarettes per day, were randomized Alpha-Tocopherol, Beta-Carotene Cancer Prevention Study Controls: participants from the same study who were alive at the time the case was diagnosed and free from cancer (except nonmelanoma skin cancer) as of December 2001. | 1) history of malignancy other than nonmelanoma cancer of the skin or carcinoma in situ 2) severe angina on exertion, 3) chronicrenal in sufficiency 4) liver cirrhosis, 5) chronic alcoholism, or other medical conditions that might limit long-term participation, 6) anticoagulant therapy 7) used supplements containing vitamin E (> 20 m g/d ), vitamin A (> 20,000 IU/d ), o r β-carotene (> 6 m g/d ) | Trial enroll: 1985 – 1988 Cases ascertained: 1985 – 2001 | Alpha-Tocopherol, Beta-Carotene Cancer Prevention Stud y | NIH | GR

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake...etc.)
17047087 | Stolzenberg-Solomon 2006 | Case-cohort study | Finland 64° N | 200 cases 400 controls | 200 cases 400 controls | 58 | 54–62 | 100% | Caucasian | BMI 26 kg/m ^ 2 ^ | Diabetes 9% Bronchial asthma 4% Mean BP = 140/90 Smoking h/o both case and controls = 90% | Vit D food 5μg Supplement 8% yes Serum 25(OH)vitamin D (D2 and D3), nmol/L 49 in cases, 46 in controls Vitamin D inadequacy (<40 nmol/L), 28% in cases, 37.2% in controls

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
17047087 | Stolzenberg-Solomon 2006 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | RIA | Y intrabatch and interbatch coefficient of variation percent of the 25(OH)D assay was 16.5%. | The interval between serum collection and diagnosis was up to 16 years (median follow-up time, 11.8 years). | . | Energy Kcal 2700 Fish 33g Eggs 47 g Milk 763 g Alcohol 9 g n-3 fatty acids 2 g saturated fat 54 g Folate 330 μg
17047087 | Stolzenberg-Solomon 2006 | Dietary calcium intake | nd | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17047087 | Stolzenberg-Solomon 2006 | Cancer | Pancreatic cancer | odds ratios (OR) for pancreatic cancer with subjects in the lowest quintile as the reference category

UI | Author Year | Comments
17047087 | Stolzenberg-Solomon 2006 | Data also available according to the seasonal variations of vit D Data also available after exclusion of cases by 5 years and 10 years

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17047087 | Stolzenberg-Solomon 2006 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Y | serum retinol
17047087 | Stolzenberg-Solomon 2006 | Demographics (e.g., age, gender, race, education)? | Yes | education, occupational activity matching based on age
17047087 | Stolzenberg-Solomon 2006 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no
17047087 | Stolzenberg-Solomon 2006 | Medical conditions | N
17047087 | Stolzenberg-Solomon 2006 | Medication | N
17047087 | Stolzenberg-Solomon 2006 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | N | Subgroup analyses based on seasonal variation Matching based on month of blood draw
17047087 | Stolzenberg-Solomon 2006 | Smoking and other life styles variables | Yes/no | smoking intensity and duration, reporting to have quit smoking > 3 consecutive visits
17047087 | Stolzenberg-Solomon 2006 | Other | N

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥;2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non- cases/Total N ** | Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
17047087 | Stolzenberg-Solomon 2006 | pancreatic cancer | < 32 | Na | Na | 27 | 80 | Age and multivariable adjusted OR of baseline fasting 25(OH)vitamin D (D2 and D3) status | OR | 1.00 | (reference) | | 0.001
17047087 | Stolzenberg-Solomon 2006 | Pancreatic cancer | > 32 and < 41.1 | | | 34 | 80 | | OR | 1.30 | (0.70–2.40) | | 0.001
17047087 | Stolzenberg-Solomon 2006 | Pancreatic cancer | > 41.1 and < 51.1 | | | 47 | 80 | | OR | 2.12 | (1.15–3.90) | | 0.001
17047087 | Stolzenberg-Solomon 2006 | Pancreatic cancer | > 51.1 and < 65.5 | | | 35 | 81 | | OR | 1.50 | (0.81–2.76) | | 0.001
17047087 | Stolzenberg-Solomon 2006 | Pancreatic cancer | > 65.5 | | | 57 | 79 | | OR | 2.92 | (1.56–5.48) | | 0.001

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
17047087 | Stolzenberg-Solomon 2006 | Pancreatic cancer | Data according to seasonal variation and quintile available

UI | Author Year | Comments for Results
17047087 | Stolzenberg-Solomon 2006 | Data after excluding cases at 5 y and 10 y are available

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
17047087 | Stolzenberg, 2009 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | N | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | Y | a) Level of the exposure in comparative categories(eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders(other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
17047087 | Stolzenberg, 2009 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | N | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | Y | a) Level of the exposure in comparative categories(eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders(other than age and sex)? ** (y/n) | Y | b) Loss to follow-up<20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
17047087 | Stolzenberg, 2009 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | A
Explanation for Overall Quality Grade (if not Grade A):

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Tangrea 1997

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
9242478 | Tangrea 1997 | Post-hoc Case-cohort study on a lung cancer prevention RCT on alpha-tocopherol and beta-carotene | Participants of ATBC study; - Male; - Age 50–69 y; - Current smoker (> 5 per day); - Residents in southwestern FinlandCases (colorectal cancer): ICD-9-153 (colon) or 154 (rectum) by Finish cancer registry; Controls: 2 age, study clinic, date of blood draw matching controls (including 9 patients of another cancer) by incidence-density sampling | No serum controls (2 controls for 2 independent cases were excluded) | 1985–1993 | ATBC study | nd | TTe

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
9242478 | Tangrea 1997 | Post-hoc Case- cohort study on a lung cancer prevention RCT on alpha- tocopherol and beta-carotene | Southwestern Finland (~ 60° N) | 438 (146 cases, 292 controls) | 436 (146 cases, 290 controls) | Median 60 | 50–69 | 100 | nd | Wt=79.1 BMI=26.3 | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (e.g. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
9242478 | Tangrea 1997 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | RIA with I ^ 125 ^ [25(OH)D] Radioreceptor assay [1,25(OH) _ 2 _ D] | Intraset Coeff of Va: 9.5% [25(OH)D] and 7.5% [1,25(OH) _ 2 _ D] | nd~9 to ~12 y inferred) | nd | Vit D intake: 5.3 g/d (4% supplement user)
9242478 | Tangrea 1997 | Dietary calcium intake | FFQ | nd | nd | | | | | Ca=1.3 g/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
9242478 | Tangrea 1997 | nd | Colorectal cancer | Diagnosis of primary adenocarcinoma through the Finish cancer registry supplemented by medical records and pathology reports with pathological review
| | nd | Colon cancer | Diagnosis of primary adenocarcinoma (see above for details)
| | nd | Rectal cancer | Diagnosis of primary adenocarcinoma (see above for details)

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
9242478 | Tangrea 1997 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake Demographics (e.g., age, gender, race, education)? Anthropometrics (e.g., BMI, body weight, % body fat)? Medical conditions br>Medication Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) Other | Yes (fat, fiber, protein, calcium, cholesterol, alpha-tocopherol, beta-carotene) Yes (matched on age, education) Yes (BMI) No No Yes (residence) Yes (physical activity, marital status, smoking history) Yes (Tx allocation of alpha-tocopherol and beta- carotene)

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥ 2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | No. of Non- cases/Total N** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups*** | P for trend****
9242478 | Tangrea 1997 | Colorectal cancer | [25(OH)D] Q1 | −9.8 | nd | 46 | 72 | crude | RR | 1.0 | - | nd | 0.13
9242478 | Tangrea 1997 | Colorectal cancer | Q2 | >9.8– 13.9 | nd | 35 | 73 | crude | RR | 0.7 | 0.4– 1.3 | nd | 0.13
9242478 | Tangrea 1997 | Colorectal cancer | Q3 | >13.9– 19.3 | nd | 36 | 73 | crude | RR | 0.8 | 0.4– 1.3 | nd | 0.13
9242478 | Tangrea 1997 | Colorectal cancer | Q4 | >19.3 | nd | 29 | 72 | crude | RR | 0.6 | 0.3– 1.1 | nd | 0.13
9242478 | Tangrea 1997 | Colon cancer | [25(OH)D]Q1 | −9.8 | nd | 30 | 47 | crude | RR | 1.0 | - | nd | 0.69
9242478 | Tangrea 1997 | Colon cancer | Q2 | >9.8– 13.9 | nd | 18 | 47 | crude | RR | 0.6 | 0.3– 1.2 | nd | 0.69
9242478 | Tangrea 1997 | Colon cancer | Q3 | >13.9– 19.3 | nd | 22 | 45 | crude | RR | 0.8 | 0.4– 1.6 | nd | 0.69
9242478 | Tangrea 1997 | Colon cancer | Q4 | >19.3 | nd | 21 | 42 | crude | RR | 0.8 | 0.4-1.6 | nd | 0.69
9242478 | Tangrea 1997 | Colon cancer (excluding the 2 y RCT period) | [25(OH)D] Q1 | −9.8 | nd | 19 | 38 | crude | RR | 1.0 | - | nd | 0.58
9242478 | Tangrea 1997 | Colon cancer (excluding the 2 y RCT period) | Q2 | >9.8– 13.9 | nd | 13 | 35 | crude | RR | 0.8 | 0.3– 1.8 | nd | 0.58
9242478 | Tangrea 1997 | Colon cancer (excluding the 2 y RCT period) | Q3 | >13.9– 19.3 | nd | 19 | 32 | crude | RR | 1.2 | 0.5– 2.8 | nd | 0.58
9242478 | Tangrea 1997 | Colon cancer (excluding the 2 y RCT period) | Q4 | >19.3 | nd | 17 | 31 | crude | RR | 1.2 | 0.5–2.8 | nd | 0.58
9242478 | Tangrea 1997 | Rectal cancer | [25(OH)D] Q1 | −9.8 | nd | 16 | 25 | crude | RR | 1.0 | - | nd | 0.06
9242478 | Tangrea 1997 | Rectal cancer | Q2 | >9.8– 13.9 | nd | 17 | 26 | crude | RR | 0.9 | 0.4– 2.4 | nd | 0.06
9242478 | Tangrea 1997 | Rectal cancer | Q3 | >13.9– 19.3 | nd | 14 | 28 | crude | RR | 0.8 | 0.3– 2.0 | nd | 0.06
9242478 | Tangrea 1997 | Rectal cancer | Q4 | >19.3 | nd | 8 | 30 | crude | RR | 0.4 | 0.1-1.1 | nd | 0.06
9242478 | Tangrea 1997 | Rectal cancer (excluding the 2 y RCT period) | [25(OH)D] Q1 | −9.8 | nd | 12 | 15 | crude | RR | 1.0 | - | nd | 0.04
9242478 | Tangrea 1997 | Rectal cancer (excluding the 2 y RCT period) | Q2 | >9.8– 13.9 | nd | 13 | 16 | crude | RR | 0.8 | 0.2– 2.4 | nd | 0.04
9242478 | Tangrea 1997 | Rectal cancer (excluding the 2 y RCT period) | Q3 | >13.9– 19.3 | nd | 7 | 21 | crude | RR | 0.4 | 0.1– 1.3 | nd | 0.04
9242478 | Tangrea 1997 | Rectal cancer (excluding the 2 y RCT period) | Q4 | >19.3 | nd | 7 | 25 | crude | RR | 0.3 | 0.1– 1.1 | nd | 0.04

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non- cases/Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
9242478 | Tangrea 1997 | Colorectal cancer | [1,25(OH)2D] Q1 | −31.7 | nd | 32 | 72 | crude | RR | 1.0 | - | nd | 0.76
9242478 | Tangrea 1997 | Colorectal cancer | Q2 | >31.7– 37.3 | nd | 43 | 72 | crude | RR | 1.3 | 0.8– 2.4 | nd | 0.76
9242478 | Tangrea 1997 | Colorectal cancer | Q3 | >37.3– 43.1 | nd | 41 | 74 | crude | RR | 1.2 | 0.7– 2.2 | nd | 0.76
9242478 | Tangrea 1997 | Colorectal cancer | Q4 | >43.1 | nd | 30 | 72 | crude | RR | 0.9 | 0.5– 1.7 | nd | 0.76
9242478 | Tangrea 1997 | Colon cancer | [1,25(OH)2D]Q1 | −31.7 | nd | 20 | 51 | crude | RR | 1.0 | - | | 0.80
9242478 | Tangrea 1997 | Colon cancer | Q2 | >31.7– 37.3 | nd | 29 | 44 | crude | RR | 1.7 | 0.8– 3.4 | | 0.80
9242478 | Tangrea 1997 | Colon cancer | Q3 | >37.3– 43.1 | nd | 20 | 41 | crude | RR | 1.2 | 0.6– 2.6 | | 0.80
9242478 | Tangrea 1997 | Colon cancer | Q4 | >43.1 | nd | 22 | 45 | crude | RR | 1.2 | 0.6-2.6 | | 0.80
9242478 | Tangrea 1997 | Colon cancer (excluding the 2 y RCT period) | [1,25(OH)2D]Q1 | -31.7 | nd | 12 | 21 | crude | RR | 1.0 | - | nd | 0.39
9242478 | Tangrea 1997 | Colon cancer (excluding the 2 y RCT period) | Q2 | >31.7- 37.3 | nd | 14 | 28 | crude | RR | 0.7 | 0.3- 2.2 | nd | 0.39
9242478 | Tangrea 1997 | Colon cancer (excluding the 2 y RCT period) | Q3 | >37.3- 43.1 | nd | 21 | 33 | crude | RR | 1.0 | 0.4- 2.5 | nd | 0.39
9242478 | Tangrea 1997 | Colon cancer (excluding the 2 y RCT period) | Q4 | >43.1 | nd | 8 | 27 | crude | RR | 0.5 | 0.2- 1.5 | nd | 0.39

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

MEAN DATA

THIS SHOULD ONLY APPLY TO CASE-COHORT STUDIES THAT COMPARE BASELINE VIT D/CA LEVELS BETWEEN CASES (WITH DISEASE) AND CONTROLS (WITHOUT DISEASE)

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or analysis? | No. Analyzed | Mean 25(OH)D Level | Vit D level CI | Mean Ca intake or Ca balance | Ca CI/SE/SD* | P between groups
9242478 | Tangrea 1997 [25(OH)D] | Cases: | Nd | Crude | 146 | 12.2 | 11.2– 13.2 | nd | Nd | <0.01
9242478 | Tangrea 1997 [25(OH)D] | Control: | Nd | Crude | 290 | 13.8 | 13.1– 14.5 | nd | Nd | <0.01
9242478 | Tangrea 1997 [1,25(OH)2D] | Cases: | nd | crude | 146 | 36.5 | 35.2– 37.8 | nd | nd | NS
9242478 | Tangrea 1997 [1,25(OH)2D] | Control: | nd | crude | 290 | 36.7 | 35.7–37.7 | nd | nd | NS

Duplicate one table per outcome

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
9242478 | Tangrea 1997 | Only univariate/crude analysis (controlled only for matching factors) was reported as the results based on multivariate model were comparable to non- adjusted analysis.

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
9242478 | Tangrea 1997 | a) Eligibility clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | Y | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | Y | a) Level of the exposure in comparative categories (e.g. quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
9242478 | Tangrea 1997 | b) Sampling of population random or consecutive? (y/n) | nd | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | N | a) Level of the exposure in comparative categories (e.g. quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
9242478 | Tangrea 1997 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | N | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Post-hoc assessment of a cohort of another RCT with multiple subgroup analyses. Family history not considered in adjustment.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Terry 2002

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
12467133 | Terry 2002 | Cohort study | Women born between 1914 – 1948 who received invitation to participate in mammography screening program and also completed and returned a six- page questionnaire including items about age, weight (kg), height (cm), education, and diet | Women > 76 years old; women whose questionnaires had missing or incorrect national identification numbers, were nit properly dated or lacked the date the woman moved out of the study area; women whose date of death were verified through the Swedish Death Registry; women with answers in the dietary portion of the questionnaire suggesting they had extreme energy intakes (3 SD below or above the mean value for natural logarithmically transformed calories using cut points of 417 and 3729 kcal) or had carelessly completed the dietary questionnaire; women with a previous cancer diagnosis (by linkage to the Swedish Cancer Registry) | 1987–1990 | Swedish Mammography Screening Cohort | Swedish Cancer Society and Swedish Research Council | AT

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
12467133 | Terry 2002 | Cohort study | Vastmanland county (59°45'N) and Uppsala county (59°53'N), Sweden | 61463 This number is smaller than the number of women reported at the baseline data table | 61463 | According to calcium intake quartile Age: 1 ^ st ^ quartile:53; 2 ^ nd ^ quartile: 52; 3 ^ rd ^ quartile: 52; 4 ^ th ^ quartile: 53 | nd | 0 | Swedish | According to calcium intake quartile BMI (Kg/m ^ 2 ^ ) (unclear whether it is mean or median): 1 ^ st ^ quartile:24.2; 2 ^ nd ^ quartile: 24; 3 ^ rd ^ quartile: 24.1; 4 ^ th ^ quartile: 24.5 | nd | Calcium intake, median (mg/day): 688 (IQR 486–914) Vitamin D intake, median (μg/day): 3.2 (IQR 2.9–3.7)

UI | Author Year | Study Design* | Location (e.g., City and Country, latitude) | N enrolled*** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
12467133 | Terry 2002 | Cohort study | Vastmanland county and Uppsala county, Sweden | 61463 This number is smaller than the number of women reported at the basely data table | 61463 | According to calcium intake quartile Mean age: 1 ^ st ^ quartile:53; 2 ^ nd ^ quartile: 52; 3 ^ rd ^ quartile: 52; 4 ^ th ^ quartile: 53 | nd | 0 | Swedish | According to calcium intake quartile BMI (Kg/m ^ 2 ^ ) (unclear whether it is mean or median): 1 ^ st ^ quartile:24.2; 2 ^ nd ^ quartile: 24; 3 ^ rd ^ quartile: 24.1; 4 ^ th ^ quartile: 24.5 | nd | According to calcium intake quartile Energy(kcal/day): 1 ^ st ^ quartile:1266;2 ^ nd ^ quartile: 1331; 3 ^ rd ^ quartile: 1349; 4 ^ th ^ quartile: 1265 Total fat (g/day): 1 ^ st ^ quartile: 42.2; 2 ^ nd ^ quartile: 42.2; 3 ^ rd ^ quartile: 42.7; 4 ^ th ^ quartile: 42.8 Dietary fiber (g/day): 1 ^ st ^ quartile: 16.6; 2 ^ nd ^ quartile: 16; 3 ^ rd ^ quartile: 15.6; 4 ^ th ^ quartile: 14.9 Vitamin C (mg/day): 1 ^ st ^ quartile: 58.8; 2 ^ nd ^ quartile: 58.9; 3 ^ rd ^ quartile: 58.1; 4 ^ th ^ quartile: 56.2 Folic acid (μg/day): 1 ^ st ^ quartile:170; 2 ^ nd ^ quartile: 176; 3 ^ rd ^ quartile: 180; 4 ^ th ^ quartile: 186

UI | Author Year | Study Design* | Location (e.g., City and Country, latitude) | N enrolled*** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
12467133 | Terry 2002 | Cohort study | Vastmanland county and Uppsala county, Sweden | 61463 This number is smaller than the number of women reported at the basely data table | 61463 | According to calcium intake quartile Age: 1 ^ st ^ quartile:53; 2 ^ nd ^ quartile: 52; 3 ^ rd ^ quartile: 52; 4 ^ th ^ quartile: 53 | nd | 0 | Swedish | According to calcium intake quartile BMI (Kg/m ^ 2 ^ ) (unclear whether it is mean or median): 1 ^ st ^ quartile:24.2; 2 ^ nd ^ quartile: 24; 3 ^ rd ^ quartile: 24.1; 4 ^ th ^ quartile: 24.5 | nd | According to calcium intake quartile Fruit and vegetables (servings/wk): 1 ^ st ^ quartile:25.3; 2 ^ nd ^ quartile: 26.7; 3 ^ rd ^ quartile: 26.2; 4 ^ th ^ quartile: 24.8 Red meat(servings/wk): 1 ^ st ^ quartile:5.1; 2 ^ nd ^ quartile: 5.1; 3 ^ rd ^ quartile: 4.6; 4 ^ th ^ quartile: 4.1 Alcohol (drinks/wk): 1 ^ st ^ quartile: 2.1; 2 ^ nd ^ quartile: 2.2; 3 ^ rd ^ quartile: 2.3; 4 ^ th ^ quartile: 2

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
12467133 | Terry 2002 | 25(OH)D and/or1,25(OH) _ 2 _ D | | | | na | na | na | na | na
12467133 | Terry 2002 | Dietary calcium intake | Self administered FFQ | Swedish National Food Administration Data | y Validity evaluated for129 of the 213 women who weighed and recorded what they consumed during 4 7- day periods at 3 to 4 month intervals. Validity estimates for dietary calcium intake: 0.5(Pearson’s correlation coefficient between FFQ and Food records) | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
12467133 | Terry 2002 | primary | Colorectal cancer | Matching two independent sources: computerized Regional Cancer Registries and a list of all pathology reportsfrom the two pathology departments covering the study area (until December 31, 1998) For the last two years of follow up (through December 31, 2000) matching with computerized Regional Cancer Registry only
| | secondary | Colon cancer | Cancer occurring above the peritoneal delineation of the abdominal cavity
| | secondary | Rectal cancer | Cancer occurring below the peritoneal delineation of the abdominal cavity
| | secondary | Proximal colon cancer | Cancer occurring from the cecum through the splenic flexure
| | secondary | Distal colon cancer | Cancer occurring from the descending colon through the sigmoid colon

UI | Author Year | Comments
12467133 | Terry 2002 | Average duration of follow up: 11.3 years. Age, BMI, nutrition status are given as mean, or median per calcium intake quartile at baseline. Median values for the total cohort are given only for calcium intake and vitamin D.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
12467133 | Terry 2002 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake Demographics (e.g., age, gender, race, education)? Anthropometrics (e.g., BMI, body weight, % body fat)? Medical conditions Medication Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) Other | Yes (red meat, energy adjusted folic acid and vitamin C consumption quartiles, energy adjusted nutrients) Yes (age: in 5 year age groups; education level: less than high school, high school, university) Yes (BMI in quartiles) No No No Yes (alcohol consumption)

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

Age adjusted model

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non- cases/Total N ** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups *** | P for trend ****
12467133 | Terry 2002 | CRC | 1 ^ st ^ total calcium intake quartile (median±SD, mg/day) | | 486±79 | 156 | nd | 135.6 | adjusted | RR | 1.00 | | | 0.04
| | CRC | 2 ^ nd ^ quartile total calcium intake (median±SD, mg/day) | | 631±34 | 149 | nd | 135.6 | adjusted | RR | 0.97 | 0.77–1.21 | nd | 0.04
| | CRC | 3 ^ rd ^ quartile total calcium intake (median±SD, mg/day) | | 747±37 | 145 | nd | 135.6 | adjusted | RR | 0.96 | 0.77–1.21 | nd | 0.04
| | CRC | 4 ^ th ^ quartile total calcium intake (median±SD, mg/day) | | 914±136 | 122 | nd | 135.6 | adjusted | RR | 0.77 | 0.61–0.98 | nd | 0.04

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

Multivariate model including age, BMI, education level, red meat intake, alcohol consumption, energy adjusted saturated fat, folic acid, vitamin C, and vitamin D intake

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | No. of Non- cases/Total N** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI** | P between groups*** | P for trend****
12467133 | Terry 2002 | CRC | 1 ^ st ^ quartile total calcium intake(median±SD, mg/day) | | 486±79 | 156 | nd | 135.6 | adjusted | RR | 1.00 | | | 0.02
| | CRC | 2 ^ nd ^ quartile total calcium intake(median±SD, mg/day) | | 631±34 | 149 | nd | 135.6 | adjusted | RR | 0.97 | 0.77–1.21 | nd | 0.02
| | CRC | 3 ^ rd ^ quartile total calcium intake(median±SD, mg/day) | | 747±37 | 145 | nd | 135.6 | adjusted | RR | 0.95 | 0.75–1.20 | nd | 0.02
| | CRC | 4 ^ th ^ quartile total calcium intake(median±SD, mg/day) | | 914±136 | 122 | nd | 135.6 | adjusted | RR | 0.72 | 0.56–0.93 | nd | 0.02

Age adjusted model

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | No. of Non- cases/Total N** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI** | P between groups*** | P for trend****
12467133 | Terry 2002 | Colon cancer | 1 ^ st ^ quartile (median±SD, mg/day) | | 486±79 | 100 | nd | 135.6 | adjusted | RR | 1.00 | | | 0.17
| | | 2 ^ nd ^ quartile (median±SD, mg/day) | | 631±34 | 97 | nd | 135.6 | adjusted | RR | 0.98 | 0.74–1.30 | nd | 0.17
| | | 3 ^ rd ^ quartile (median±SD, mg/day) | | 747±37 | 92 | nd | 135.6 | adjusted | RR | 0.95 | 0.72–1.27 | nd | 0.17
| | | 4 ^ th ^ quartile (median±SD, mg/day) | | 914±136 | 82 | nd | 135.6 | adjusted | RR | 0.81 | 0.61–1.09 | nd | 0.17
| | Rectal cancer | 1 ^ st ^ quartile (median±SD, mg/day) | | 486±79 | 55 | nd | 135.6 | adjusted | RR | 1.00 | | nd | 0.11
| | | 2 ^ nd ^ quartile (median±SD, mg/day) | | 631±34 | 48 | nd | 135.6 | adjusted | RR | 0.90 | 0.61–1.32 | nd | 0.11
| | | 3 ^ rd ^ quartile (median±SD, mg/day) | | 747±37 | 49 | nd | 135.6 | adjusted | RR | 0.92 | 0.62–1.36 | nd | 0.11
| | | 4 ^ th ^ quartile (median±SD, mg/day) | | 914±136 | 39 | nd | 135.6 | adjusted | RR | 0.70 | 0.46–1.06 | nd | 0.11

Multivariate model including age, BMI, education level, red meat intake, alcohol consumption, energy adjusted saturated fat, folic acid, vitamin C, and vitamin D intake

UI | Author Year | Outcome | Exposure Categories (e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | No. of Non- cases/Total N** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI** | P between groups*** | P for trend****
12467133 | Terry 2002 | Colon cancer | 1 ^ st ^ quartile (median±SD, mg/day) | | 486±79 | 100 | nd | 135.6 | adjusted | RR | 1.00 | | | 0.06
| | | 2 ^ nd ^ quartile (median±SD, mg/day) | | 631±34 | 97 | nd | 135.6 | adjusted | RR | 0.97 | 0.74–1.30 | nd | 0.06
| | | 3 ^ rd ^ quartile (median±SD, mg/day) | | 747±37 | 92 | nd | 135.6 | adjusted | RR | 0.93 | 0.70–1.24 | nd | 0.06
| | | 4 ^ th ^ quartile (median±SD, mg/day) | | 914±136 | 82 | nd | 135.6 | adjusted | RR | 0.74 | 0.54–1.01 | nd | 0.06
| | Rectal cancer | 1 ^ st ^ quartile (median±SD, mg/day) | | 486±79 | 55 | nd | 135.6 | adjusted | RR | 1.00 | | nd | 0.12
| | | 2 ^ nd ^ quartile (median±SD, mg/day) | | 631±34 | 48 | nd | 135.6 | adjusted | RR | 0.89 | 0.60–1.32 | nd | 0.12
| | | 3 ^ rd ^ quartile (median±SD, mg/day) | | 747±37 | 49 | nd | 135.6 | adjusted | RR | 0.94 | 0.63–1.39 | nd | 0.12
| | | 4 ^ th ^ quartile (median±SD, mg/day) | | 914±136 | 39 | nd | 135.6 | adjusted | RR | 0.70 | 0.45–1.09 | nd | 0.12

Women < 55 years old vs. women ≥ 55 years old

Multivariate model including age, BMI, education level, red meat intake, alcohol consumption, energy adjusted saturated fat, folic acid, vitamin C, and vitamin D intake

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | No. of Non- cases/Total N** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI** | P between groups*** | P for trend****
12467133 | Terry 2002 | Colon cancer | Women < 55 years 1 ^ st ^ quartile (mg/day) | | 176 to<568 | nd | nd | 135.6 | adjusted | RR | 1.00 | | | 0.92
| | Colon cancer | Women < 55 years 2 ^ nd ^ quartile (mg/day) | | 568 to<688 | nd | nd | 135.6 | adjusted | RR | 1.32 | 0.75–2.30 | nd | 0.92
| | Colon cancer | Women < 55 years 3 ^ rd ^ quartile (mg/day) | | 688 to<816 | nd | nd | 135.6 | adjusted | RR | 1.02 | 0.55–1.85 | nd | 0.92
| | Colon cancer | Women < 55 years 4 ^ th ^ quartile (mg/day) | | 816 to1300 | nd | nd | 135.6 | adjusted | RR | 1.11 | 0.60–2.05 | nd | 0.92
| | Rectal cancer | Women < 55 years 1 ^ st ^ quartile (mg/day) | | 176 to<568 | nd | nd | 135.6 | adjusted | RR | 1.00 | | | 0.75
| | Rectal cancer | Women < 55 years 2 ^ nd ^ quartile (mg/day) | | 568 to<688 | nd | nd | 135.6 | adjusted | RR | 0.33 | 0.34–1.59 | nd | 0.75
| | Rectal cancer | Women < 55 years 3 ^ rd ^ quartile (mg/day) | | 688 to<816 | nd | nd | 135.6 | adjusted | RR | 1.30 | 0.66–2.56 | nd | 0.75
| | Rectal cancer | Women < 55 years 4 ^ th ^ quartile (mg/day) | | 816 to1300 | nd | nd | 135.6 | adjusted | RR | 0.70 | 0.31–1.62 | nd | 0.75
| | Colorectal cancer | Women < 55 years 1 ^ st ^ quartile (mg/day) | | 176 to <568 | nd | nd | 135.6 | adjusted | RR | 1.00 | | | 0.77
| | Colorectal cancer | Women < 55 years 2 ^ nd ^ quartile (mg/day) | | 568 to<688 | nd | nd | 135.6 | adjusted | RR | 1.06 | 0.68–1.66 | nd | 0.77
| | Colorectal cancer | Women < 55 years 3 ^ rd ^ quartile (mg/day) | | 688 to<816 | nd | nd | 135.6 | adjusted | RR | 1.11 | 0.71–1.73 | nd | 0.77
| | Colorectal cancer | Women < 55 years 4 ^ th ^ quartile (mg/day) | | 816 to1300 | nd | nd | 135.6 | adjusted | RR | 0.91 | 0.56–1.48 | nd | 0.77
| | Colorectal cancer | Women ≥ 55 years 1 ^ st ^ quartile (mg/day) | | 176 to<568 | nd | nd | 135.6 | adjusted | RR | 1.00 | | | 0.008
| | Colorectal cancer | Women ≥ 55 years 2 ^ nd ^ quartile (mg/day) | | 568 to<688 | nd | nd | 135.6 | adjusted | RR | 0.93 | 0.71–1.21 | nd | 0.008
| | Colorectal cancer | Women ≥ 55 years 3 ^ rd ^ quartile (mg/day) | | 688 to<816 | nd | nd | 135.6 | adjusted | RR | 0.89 | 0.68–1.17 | nd | 0.008
| | Colorectal cancer | Women ≥ 55 years 4 ^ th ^ quartile (mg/day) | | 816 to1300 | nd | nd | 135.6 | adjusted | RR | 0.66 | 0.49–0.89 | nd | 0.008
| | Colon cancer | Women ≥ 55 years 1 ^ st ^ quartile (mg/day) | | 176 to<568 | nd | nd | 135.6 | adjusted | RR | 1.00 | | | 0.02
| | Colon cancer | Women ≥ 55 years 2 ^ nd ^ quartile (mg/day) | | 568 to<688 | nd | nd | 135.6 | adjusted | RR | 0.89 | 0.64–1.23 | nd | 0.02
| | Colon cancer | Women ≥ 55 years 3 ^ rd ^ quartile (mg/day) | | 688 to<816 | nd | nd | 135.6 | adjusted | RR | 0.91 | 0.65–1.26 | nd | 0.02
| | Colon cancer | Women ≥ 55 years 4 ^ th ^ quartile (mg/day) | | 816 to1300 | nd | nd | 135.6 | adjusted | RR | 0.64 | 0.44–0.92 | nd | 0.02
| | Rectal cancer | Women ≥ 55 years 1 ^ st ^ quartile (mg/day) | | 486 | nd | nd | 135.6 | adjusted | RR | 1.00 | | | 0.15
| | Rectal cancer | Women ≥ 55 years 2 ^ nd ^ quartile (mg/day) | | 631 | nd | nd | 135.6 | adjusted | RR | 0.96 | 0.61–1.52 | nd | 0.15
| | Rectal cancer | Women ≥ 55 years 3 ^ rd ^ quartile (mg/day) | | 747 | nd | nd | 135.6 | adjusted | RR | 0.79 | 0.48–1.29 | nd | 0.15
| | Rectal cancer | Women ≥ 55 years 4 ^ th ^ quartile (mg/day) | | 914 | nd | nd | 135.6 | adjusted | RR | 0.70 | 0.42–1.19 | nd | 0.15

QUALITY OF COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
| | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | N | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
| | b) Sampling of population random or consecutive? (y/n) | N | b) Outcome assessor blinded to exposure measurement? (y/n) | N | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | Y
| | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Y | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Number of women when baseline data are presented is inconsistent (larger) with the sample size reported in the methods section; blinding assessor not reported; number of non-cases per calcium intake quartile is not given; also number of cases and non-cases in the subgroup analyses by age; statistical methods to compare all different subgroups per cancer type, in the analysis by age, are not applied; power calculations are not reported; confirmation of cases by histology not reported for al participants

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Thomsen 1987

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
3307307 | Thomsen 1987 | RCT | Early post-menopausal women without history of diseases or receiving drugs known to influence calcium metabolism or the cardiovascular system. | nd | nd | nd | nd | KP

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
3307307 | Thomsen 1987 | RCT | Copenhagen, Denmark 55°40′ N | 28 | 28 | nd | nd | 0% | nd | nd | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
3307307 | Thomsen 1987 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | nd | nd | nd | nd
3307307 | Thomsen 1987 | Dietary calcium intake | nd | nd | nd | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
3307307 | Thomsen 1987 | Calcium | Sandoz (calcium lactate-gluconate, calcium carbonate) | 2,000 mg | One year | nd
| | placebo
Co-intervention(s) * :
Compliance/Adherence: | | | nd

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
3307307 | Thomsen 1987 | nd | Bodyweight | Change in kg/yr

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
3307307 | Thomsen 1987 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
3307307 | Thomsen 1987 | Demographics (e.g., age, gender, race, education)? | No
3307307 | Thomsen 1987 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No
3307307 | Thomsen 1987 | Medical conditions
3307307 | Thomsen 1987 | Medication
3307307 | Thomsen 1987 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
3307307 | Thomsen 1987 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | No
3307307 | Thomsen 1987 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline CI/SE/SD * | Final or Delta ** | Final or Delta CI/SE/SD * | Net difference | Net difference CI/SE/SD * | P between
3307307 | Thomsen 1987 | Bodyweight change | Kg | Calcium | 1 yr | 14 | 60.6 | SD = 5.4 | 61.0 | SD = 5.1 | −0.2 | ND | Not significant
3307307 | Thomsen 1987 | Bodyweight change | Kg | placebo | 1 yr | 14 | 66.4 | SD = 13.8 | 67.0 | SD = 14.0

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−” sign: e.g. +2.8 or −2.8

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
3307307 | Thomsen 1987 | RCT- parallel | Y | nd | nd | nd | nd | nd | nd | N | Y | C
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Poorly described methods and demographics. Large baseline difference in weight.

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Trivedi 2003

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
12609940 | Trivedi 2003 | RCT | - Men & women ***; - 65–85 years ***; - The British doctor study register or the sex-age register of a GP in Ipswich, Suffolk *** | - Already Vit D supplements takers; - Contraindication to Vit D (eg, renal stone, sarcoidosis, malignancy) | 06/96-03/97 | Nd | Medical Research Council, UK | TTe

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

*** Registry participants to which a recruit mail sent (n=11120), who agreed to participate (n=3504 [32%])

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
12609940 | Trivedi 2003 | RCT | UK (Oxford [ 52°N ] & Ipswich [ 52°N ]) | 2686 | 2686 | 75 (5) | 65–85 *** * | 76 | nd | BMI=24.4 | Hx of CAD: 16% Hx of stroke: 4% Hx of CVD: 28% Hx of cancer Steroids user: 5% Hormone replacement therapy (female): 7% Physically active (>moderately): 84% | Mean total Ca intake at 4 year after start of the intervention: 742 mg/d

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed information as possible on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Inclusion criteria

CAD = coronary artery disease/ischemic heart disease; CVD = cardiovascular disease comprising CAD, stroke, and other cardiac diseases

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
12609940 | Trivedi 2003 | 25(OH)D at 4 years after the intervention in the placebo group (n=114 only) | | | | nd | nd | nd | nd | 53.4 nmol/L
12609940 | Trivedi 2003 | Dietary calcium intake | nd | nd | nd | NA | NA | | | Mean total Ca intake at 4 year after start of the intervention: 742 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
12609940 | Trivedi 2003 | Vit D | Vit D3 (cholecalciferol) | 100,000 IU q 4 months (~833 IU/d) | 5 years (15 total doses) | 1 cap q 4 mo
| | Placebo | Matching placebo
Co-intervention(s) * : | | | Participants continued any usual medications (only data on steroids and hormone replacement therapy reported)
Compliance/Adherence: | | | 76% with at least 80% compliance; 66% at last dose (80% if excluding deaths)

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
12609940 | Trivedi 2003 | Secondary | All cause mortality | Death certificate (based on ICD-9 * ) by investigators blinded to the intervention ***
| | Secondary | Cardiovascular disease mortality | same as above
| | Secondary | Ischemic heart disease mortality | same as above
| | Secondary | Cerebrovascular disease mortality | same as above
| | Secondary | All cancers mortality | same as above
| | Secondary | Colorectal caner mortality | same as above
| | Secondary | Respiratory cancer mortality | same as above
| | Secondary | Breast cancer mortality (female) | same as above
| | Secondary | Cardiovascular disease incidence | Death certificate (ICD-9 * ) and self-reported questionnaire data ***
| | Secondary | Ischemic heart disease incidence | same as above
| | Secondary | Cerebrovascular disease incidence | same as above
| | Secondary | All cancers incidence | same as above
| | Secondary | Colorectal cancer incidence | same as above
| | Secondary | Respiratory cancer incidence | same as above
| | Secondary | Breast cancer incidence (female) | same as above
| | Secondary | Falls incidence | same as above

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

* Cardiovascular disease=ICD-9 codes 390.0–459.9; ischaemic heart disease=410.0–414.0; cerebrovascular disease=430.0–438.0; all cancers=140.0–239.9; colorectal cancer=153.0–154.8; respiratory cancer=160.0–165.9; breast cancer=174.0–175.0

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

*** None of the causes were verified independently (e.g. by medical charts or pathology reports)

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
12609940 | Trivedi 2003 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | No
12609940 | Trivedi 2003 | Demographics (e.g., age, gender, race, education)? | Yes (Age, gender [subgroup])
12609940 | Trivedi 2003 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No
12609940 | Trivedi 2003 | Medical conditions | No
12609940 | Trivedi 2003 | Medication | No
12609940 | Trivedi 2003 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | No
12609940 | Trivedi 2003 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | No
12609940 | Trivedi 2003 | Other | None

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure/Intervention | Max Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Max Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | Result | 95% CI | P btw
12609940 | Trivedi 2003 | Mortality Men and Women
12609940 | Trivedi 2003 | Mortality Men and Women
| | All Causes | Vit D | 60–69 | 224 | 1345 | HR | | | | 0.88 | 0.74–1.06 | 0.18
| | All Causes | Placebo | | 247 | 1341 | HR | | | | 0.88 | 0.74–1.06 | 0.18
| | Cardiovascular Disease | Vit D | 60–69 | 101 | 1345 | HR | | | | 0.84 | 0.65–1.1 | 0.2
| | Cardiovascular Disease | Placebo | | 117 | 1341 | HR | | | | 0.84 | 0.65–1.1 | 0.2
| | Ischaemic Heart Disease | Vit D | 60–69 | 42 | 1345 | HR | | | | 0.84 | 0.56–1.27 | 0.41
| | Ischaemic Heart Disease | Placebo | | 49 | 1341
| | Cerebrovascular Disease | Vit D | 60–69 | 28 | 1345 | HR | | | | 1.04 | 0.61–1.77 | 0.89
| | Cerebrovascular Disease | Placebo | | 26 | 1341 | HR | | | | 1.04 | 0.61–1.77 | 0.89
| | All Cancers | Vit D | 60–69 | 63 | 1345 | HR | | | | 0.86 | 0.61–1.2 | 0.37
| | All Cancers | Placebo | | 72 | 1341 | HR | | | | 0.86 | 0.61–1.2 | 0.37
| | Colorectal | Vit D | 60–69 | 7 | 1345 | HR | | | | 0.62 | 0.24–1.6 | 0.33
| | Colorectal | Placebo | | 11 | 1341 | HR | | | | 0.62 | 0.24–1.6 | 0.33
| | Respirary | Vit D | 60–69 | 10 | 1345 | HR | | | | 0.89 | 0.38–2.09 | 0.78
| | Respirary | Placebo | | 11 | 1341 | HR | | | | 0.89 | 0.38–2.09 | 0.78
| | Mortality Men
| | Mortality Men
| | All Causes | Vit D | 60–69 | 199 | 1019 | HR | | | | 0.88 | 0.73–1.07 | 0.19
| | All Causes | Placebo | | 220 | 1018 | HR | | | | 0.88 | 0.73–1.07 | 0.19
| | Cardiovascular Disease | Vit D | 60–69 | 90 | 1019 | HR | | | | 0.83 | 0.62–1.1 | 0.19
| | Cardiovascular Disease | Placebo | | 106 | 1018 | HR | | | | 0.83 | 0.62–1.1 | 0.19
| | Ischaemic Heart Disease | Vit D | 60–69 | 38 | 1019 | HR | | | | 0.83 | 0.54–1.28 | 0.4
| | Ischaemic Heart Disease | Placebo | | 45 | 1018 | HR | | | | 0.83 | 0.54–1.28 | 0.4
| | Cerebrovascular Disease | Vit D | 60–69 | 24 | 1019 | HR | | | | 0.92 | 0.52–1.61 | 0.77
| | Cerebrovascular Disease | Placebo | | 25 | 1018 | HR | | | | 0.92 | 0.52–1.61 | 0.77
| | All Cancers | Vit D | 60–69 | 56 | 1019 | HR | | | | 0.93 | 0.64–1.34 | 0.69
| | All Cancers | Placebo | | 59 | 1018 | HR | | | | 0.93 | 0.64–1.34 | 0.69
| | Colorectal | Vit D | 60–69 | 7 | 1019 | HR | | | | 0.97 | 0.34–2.78 | 0.96
| | Colorectal | Placebo | | 7 | 1018 | HR | | | | 0.97 | 0.34–2.78 | 0.96
| | Respiratory | Vit D | 60–69 | 10 | 1019 | HR | | | | 1.08 | 0.44–2.65 | 0.87
| | Respiratory | Placebo | | 9 | 1018 | HR | | | | 1.08 | 0.44–2.65 | 0.87
| | Mortality Women
| | Mortality Women
| | All Causes | Vit D | 60–69 | 25 | 326 | HR | | | | 0.91 | 0.53–1.56 | 0.73
| | All Causes | Placebo | | 27 | 323 | HR | | | | 0.91 | 0.53–1.56 | 0.73
| | Cardiovascular Disease | Vit D | 60–69 | 11 | 326 | HR | | | | 0.99 | 0.43–2.3 | 0.99
| | Cardiovascular Disease | Placebo | | 11 | 323 | HR | | | | 0.99 | 0.43–2.3 | 0.99
| | Ischaemic Heart Disease | Vit D | 60–69 | 4 | 326 | HR | | | | 0.99 | 0.25–3.96 | 0.99
| | Ischaemic Heart Disease | Placebo | | 4 | 323 | HR | | | | 0.99 | 0.25–3.96 | 0.99
| | Cerebrovascular Disease | Vit D | 60–69 | 4 | 326 | HR | | | | 3.98 | 0.44–35.64 | 0.22
| | Cerebrovascular Disease | Placebo | | 1 | 323 | HR | | | | 3.98 | 0.44–35.64 | 0.22
| | All Cancers | Vit D | 60–69 | 7 | 326 | HR | | | | 0.53 | 0.21–1.33 | 0.18
| | All Cancers | Placebo | | 13 | 323 | HR | | | | 0.53 | 0.21–1.33 | 0.18
| | Colorectal | Vit D | 60–69 | 0 | 326 | HR | | | | NA | | 0.04
| | Colorectal | Placebo | | 4 | 323 | HR | | | | NA | | 0.04
| | Respiratory | Vit D | 60–69 | 0 | 326 | HR | | | | NA | | 0.16
| | Respiratory | Placebo | | 2 | 323 | HR | | | | NA | | 0.16
| | Breast | Vit D | 60–69 | 0 | 326 | HR | | | | NA | | NA
| | Breast | Placebo | | 0 | 323 | HR | | | | NA | | NA
| | Incidence Men & Women
| | Incidence Men & Women
| | Cardiovascular Disease | Vit D | 60–69 | 477 | 1345 | HR | | | | 0.9 | 0.77–1.06 | 0.22
| | Cardiovascular Disease | Placebo | | 503 | 1341 | HR | | | | 0.9 | 0.77–1.06 | 0.22
| | IschaemicHeart Disease | Vit D | 60–69 | 224 | 1345 | HR | | | | 0.94 | 0.77–1.15 | 0.57
| | IschaemicHeart Disease | Placebo | | 233 | 1341 | HR | | | | 0.94 | 0.77–1.15 | 0.57
| | Cerebrovascular Disease | Vit D | 60–69 | 105 | 1345 | HR | | | | 1.02 | 0.77–1.36 | 0.87
| | Cerebrovascular Disease | Placebo | | 101 | 1341 | HR | | | | 1.02 | 0.77–1.36 | 0.87
| | All Cancers | Vit D | 60–69 | 188 | 1345 | HR | | | | 1.09 | 0.86–1.36 | 0.47
| | All Cancers | Placebo | | 173 | 1341 | HR | | | | 1.09 | 0.86–1.36 | 0.47
| | Cancer Excluding Skin | Vit D | 60–69 | 144 | 1345 | HR | | | | 1.11 | 0.86–1.42 | 0.43
| | Cancer Excluding Skin | Placebo | | 130 | 1341 | HR | | | | 1.11 | 0.86–1.42 | 0.43
| | Colorectal Cancer | Vit D | 60–69 | 28 | 1345 | HR | | | | 1.02 | 0.60–1.74 | 0.94
| | Colorectal Cancer | Placebo | | 27 | 1341 | HR | | | | 1.02 | 0.60–1.74 | 0.94
| | Respiratory Cancer | Vit D | 60–69 | 17 | 1345 | HR | | | | 1.12 | 0.56–2.25 | 0.75
| | Respiratory Cancer | Placebo | | 15 | 1341 | HR | | | | 1.12 | 0.56–2.25 | 0.75
| | Self Reported Falls | Vit D | 60–69 | 254 | 1027 | HR | | | | 0.93 | 0.76–1.14 | 0.5
| | Self Reported Falls | Placebo | | 261 | 1011 | HR | | | | 0.93 | 0.76–1.14 | 0.5
| | Incidence Men
| | Incidence Men
| | Cardiovascular Disease | Vit D | 60–69 | 392 | 1019 | HR | | | | 0.91 | 0.76–1.09 | 0.3
| | Cardiovascular Disease | Placebo | | 412 | 1018 | HR | | | | 0.91 | 0.76–1.09 | 0.3
| | Ischaemic Heart Disease | Vit D | 60–69 | 191 | 1019 | HR | | | | 0.98 | 0.78–1.22 | 0.86
| | Ischaemic Heart Disease | Placebo | | 193 | 1018 | HR | | | | 0.98 | 0.78–1.22 | 0.86
| | Cerebrovascular Disease | Vit D | 60–69 | 86 | 1019 | HR | | | | 0.99 | 0.72–1.36 | 0.96
| | Cerebrovascular Disease | Placebo | | 85 | 1018 | HR | | | | 0.99 | 0.72–1.36 | 0.96
| | All Cancers | Vit D | 60–69 | 163 | 1019 | HR | | | | 1.11 | 0.87–1.42 | 0.39
| | All Cancers | Placebo | | 147 | 1018 | HR | | | | 1.11 | 0.87–1.42 | 0.39
| | Cancer Excluding Skin | Vit D | 60–69 | 129 | 1019 | HR | | | | 1.17 | 0.89–1.54 | 0.26
| | Cancer Excluding Skin | Placebo | | 111 | 1018 | HR | | | | 1.17 | 0.89–1.54 | 0.26
| | Colorectal Cancer | Vit D | 60–69 | 25 | 1019 | HR | | | | 1.18 | 0.65–2.12 | 0.59
| | Colorectal Cancer | Placebo | | 21 | 1018 | HR | | | | 1.18 | 0.65–2.12 | 0.59
| | Respiratory Cancer | Vit D | 60–69 | 17 | 1019 | HR | | | | 1.29 | 0.62–2.68 | 0.49
| | Respiratory Cancer | Placebo | | 13 | 1018 | HR | | | | 1.29 | 0.62–2.68 | 0.49
| | Self Reported Falls | Vit D | 60–69 | 154 | 757 | HR | | | | 0.87 | 0.68–1.12 | 0.27
| | Self Reported Falls | Placebo | | 169 | 756 | HR | | | | 0.87 | 0.68–1.12 | 0.27
| | Incidence Women
| | Incidence Women
| | Cardiovascular Disease | Vit D | 60–69 | 85 | 326 | HR | | | | 0.89 | 0.63–1.27 | 0.52
| | Cardiovascular Disease | Placebo | | 91 | 323 | HR | | | | 0.89 | 0.63–1.27 | 0.52
| | Ischaemic Heart Disease | Vit D | 60–69 | 33 | 326 | HR | | | | 0.79 | 0.48–1.29 | 0.35
| | Ischaemic Heart Disease | Placebo | | 40 | 323 | HR | | | | 0.79 | 0.48–1.29 | 0.35
| | Cerebrovascular Disease | Vit D | 60–69 | 19 | 326 | HR | | | | 1.19 | 0.60–2.37 | 0.62
| | Cerebrovascular Disease | Placebo | | 16 | 323 | HR | | | | 1.19 | 0.60–2.37 | 0.62
| | All Cancers | Vit D | 60–69 | 25 | 326 | HR | | | | 0.95 | 0.54–1.68 | 0.85
| | All Cancers | Placebo | | 26 | 323 | HR | | | | 0.95 | 0.54–1.68 | 0.85
| | Cancer Excluding Skin | Vit D | 60–69 | 15 | 326 | HR | | | | 0.77 | 0.39–1.55 | 0.47
| | Cancer Excluding Skin | Placebo | | 19 | 323 | HR | | | | 0.77 | 0.39–1.55 | 0.47
| | Colorectal Cancer | Vit D | 60–69 | 3 | 326 | HR | | | | 0.49 | 0.12–1.98 | 0.32
| | Colorectal Cancer | Placebo | | 6 | 323 | HR | | | | 0.49 | 0.12–1.98 | 0.32
| | Respiratory Cancer | Vit D | 60–69 | 0 | 326 | HR | | | | NA | | 0.16
| | Respiratory Cancer | Placebo | | 0.6 | 323 | HR | | | | NA | | 0.16
| | Breast Cancer | Vit D | 60–69 | 4 | 326 | HR | | | | 0.99 | 0.25–3.99 | 0.99
| | Breast Cancer | Placebo | | 4 | 323 | HR | | | | 0.99 | 0.25–3.99 | 0.99
| | Self Reported Falls | Vit D | 60–69 | 100 | 270 | HR | | | | 1.03 | 0.72–1.48 | 0.86
| | Self Reported Falls | Placebo | | 92 | 255 | HR | | | | 1.03 | 0.72–1.48 | 0.86

* Example: OR Ca/placebo

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
12609940 | Trivedi 2003 | RCT | nd | nd | nd | y | y | y | y | NA | y | B
Adverse Event(s): **
Explanation for Overall Quality Grade (if not Grade A): | | | | | | No independent verification of cases identified through the death certificates and self-reported data and suboptimal reporting of methodology of randomization.

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT–Parallel, RCT–Cross-over, RCT–Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse events.

## Tseng 2005

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
15883441 | Tseng 2005 | Cohort study | | Diagnosis of prostate cancer at or before the 1982–1984 baseline interview | 1982–1984 | National Health and Nutrition Examination Survey (NHANES I) Epidemiologic Follow-up Study (NHEFS) | NIH, American Cancer Society, Department of Defense, Commonwealth of Pennsylvania | KP/SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
15883441 | Tseng 2005 | Cohort study | United States various, excluding Hawaii, Alaska, and Native American lands | 14407 | 3779 | 57.8(14.6) | 25–74 | 100% | White 88%, Black 11%, Other 1% | nd | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed information as possible on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
15883441 | Tseng 2005 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | NA | NA | NA | NA | Vitamin D dietary intake 172(101) IU/d
15883441 | Tseng 2005 | Dietary calcium intake | FFQ | No specific information, but reference to Ursin 1993 | N | | | | | Calcium 730(347) mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
15883441 | Tseng 2005 | Nd | Prostate cancer | Confirmation through histopathology reports or medical records deemed “definite” case status. “Probable” case status given when confirmation could only be confirmed through death certificates or interview.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
15883441 | Tseng 2005 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Energy intake, recreational and usual level of physical activity
15883441 | Tseng 2005 | Demographics (e.g., age, gender, race, education)? | Yes | Age, race, education
15883441 | Tseng 2005 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No
15883441 | Tseng 2005 | Medical conditions
15883441 | Tseng 2005 | Medication
15883441 | Tseng 2005 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | US region, rural/urban/suburban residence, recreational sun exposure
15883441 | Tseng 2005 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | Smoking status, current alcohol intake
15883441 | Tseng 2005 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | No. of Non- cases/Total N** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups*** | P for trend****
15883441 | Tseng 2005 | Prostate cancer | Tertile 1: Calcium median intake 455.4 mg/d | nd | nd | 28 | Nd | 7.7 yrs | Adjusted | RR | 1.0 | Reference | Nd | 0.001
| | | Tertile 2: Calcium median intake 642.1 mg/d | nd | nd | 37 | Nd | 7.7 yrs | | | 1.0 | 0.6–1.7 | Nd
| | | Tertile 3: Calcium median intake 920.6 mg/d | nd | nd | 66 | Nd | 7.7 yrs | | | 2.2 | 1.4–3.5 | nd

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
15883441 | Tseng 2005 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | N | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
15883441 | Tseng 2005 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | N | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | nd
15883441 | Tseng 2005 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | N | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Part of dietary estimates derived from recall data based on NHANES II conducted ~4 y earlier; only ~65% cases were “definite” (confirmed by histopathology or medical records), rest were “probable”.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Tuohimaa 2004

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
14618623 | Tuohimaa 2004 | Case-cohort study | enrolled in heart studies; available blood sample | | 1973; 1981–82; 1985-ongoing | Helsinki Heart Study; Janus Project; Vasterbotten Intervention Project | non-profit | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
14618623 | Tuohimaa 2004 | Case- cohort study | Helsinki, Finland; Norway; Northern Sweden | 2073 | 2073 | nd | <40 to >60 | 100 | nd | nd | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data ...etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
14618623 | Tuohimaa 2004 | 25(OH)D | | | | RIA, Incstar, MN | y; intraassay 8.5%; interassay 16% | nd | nd | nd
| | Dietary calcium intake

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
14618623 | Tuohimaa2004 | primary | prostate cancer | national cancer registries

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
14618623 | Tuohimaa 2004 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | nd
14618623 | Tuohimaa 2004 | Demographics (e.g., age, gender, race, education)? | yes | age
14618623 | Tuohimaa 2004 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no *
14618623 | Tuohimaa 2004 | Medical conditions | nd
14618623 | Tuohimaa 2004 | Medication | nd
14618623 | Tuohimaa 2004 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | yes | region
14618623 | Tuohimaa 2004 | Smoking and other life styles variables | no *
14618623 | Tuohimaa 2004 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases * | No. of Non- cases/Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
14618623 | Tuohimaa 2004 | prostate cancer | | ≤19 | | 19 | nd | conditional logistic | OR | 1.5 | 0.8–2.7
| | | | 20–39 | | 169 | nd | | | 1.3 | 0.98–1.6
| | | | 40–49 (ref) | | 229 | nd | | | 1
| | | | 60–79 | | 138 | nd | | | 1.2 | 0.9–1.5
| | | | ≥80 | | 67 | nd | | | 1.7 | 1.1–2.4

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
14618623 | Tuohimaa 2004 | used conditional logistic regression analysis to maintain matching status, but unclear which factors were matched

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
14618623 | Tuohimaa 2004 | a) Eligibility criteria clear? (y/n) | N | a) Exposure assessor blinded to outcome info? (y/n) | N | a) Method reported? (y/n) | N | a) One of the prespecified methods *** was used? (y/n) | Y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | N
14618623 | Tuohimaa 2004 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | N | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
14618623 | Tuohimaa 2004 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | unclear if additional relevant confounders were also adjusted for in analysis

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Tuohimaa 2007

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17301263 | Tuohimaa 2007 | Case-cohort study | prostate cancer | nd | 1981–82 | Helsinki Heart Study | non-profit | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
17301263 | Tuohimaa 2007 | Case- cohort study | Helsinki, Finland | 588 | 588 | 51 (3.7) | nd | 100 | nd | BMI 26.3 | subjects enrolled in gemfibrozil trial | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
17301263 | Tuohimaa 2007 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | RIA (Incstar Corp., MN) | intraassay CV: 8.5%; interassay CV: 16% | 10.8 y | nd | most sample collected during winter months
| | Dietary calcium intake

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17301263 | Tuohimaa 2007 | Primary | prostate cancer | from Finnish Cancer Registry

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17301263 | Tuohimaa 2007 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | no
17301263 | Tuohimaa 2007 | Demographics (e.g., age, gender, race, education)? | Yes
17301263 | Tuohimaa 2007 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes
17301263 | Tuohimaa 2007 | Medical conditions | Yes, BMI >28; SBP >150; HDL-C ≤1.05
17301263 | Tuohimaa 2007 | Medication | Yes
17301263 | Tuohimaa 2007 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | nd
17301263 | Tuohimaa 2007 | Smoking and other life styles variables | no *
17301263 | Tuohimaa 2007 | Other | specimens were accidentally thawed or not | 54/132 (41%) accidentally thawed

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non- cases/Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
17301263 | Tuohimaa 2007 | prostate cancer | | | | 132 (total) | 456 (total)
| | | | <40 nmol/L | | | | crude | OR | 1.93 | 1.19–3.13
| | | | 40–59 (reference) | | | | | | 1
| | | | ≥60 | | | | crude | | 1.32 | 0.69–2.56
| | | | <40 nmol/L | | | | adjusted | OR | 1.88 | 1.15–3.08
| | | | 40–59 (reference) | | | | | | 1
| | | | ≥60 | | | | adjusted | | 1.25 | 0.64–2.43

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
17301263 | Tuohimaa 2007 | some data reported in Tuohimaa 2004 UI 14618623

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
17301263 | Tuohimaa 2007 | a) Eligibility criteria clear? (y/n) | N | a) Exposure assessor blinded to outcome info? (y/n) | N | a) Method reported? (y/n) | N | a) One of the prespecified methods *** was used? (y/n) | Y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
17301263 | Tuohimaa 2007 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | Y | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | Y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
17301263 | Tuohimaa 2007 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | NA | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | 41% of the specimens were accidentally thawed; no explicit information provided for adjustment for additional factors relevant to vitamin D

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Umesawa 2006

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
16339476 | Umesawa 2006 | Cohort study | 40–79 y | Stroke, CHD, cancer, valid FFQ | 1988–1990 | Japan Collaborative Cohort | Gov’t | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
16339476 | Umesawa 2006 | Cohort study | Japan, various | 53,387 | 53,387 | 56 | 40–79 | 39% | Japanese | Men 22.7 Women 22.9 | Healthy | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
16339476 | Umesawa 2006 | Dietary calcium intake | FFQ | Japan Food Table v4 | No (data from other study reported) | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
16339476 | Umesawa 2006 | 1° | Total stroke mortality | Death certificates (ICD-9 & 10)
| | | specific stroke data | not extracted
| | 2° | Coronary heart disease mortality | Death certificates (ICD-9 & 10)
| | 2° | Total CVD mortality | Death certificates (ICD-9 & 10), “total CVD” not defined

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
16339476 | Umesawa 2006 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes | K intake, total energy intake
16339476 | Umesawa 2006 | Demographics (e.g., age, gender, race, education)? | Yes | Age
16339476 | Umesawa 2006 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI
16339476 | Umesawa 2006 | Medical conditions | Yes | HTN, DM
16339476 | Umesawa 2006 | Medication
16339476 | Umesawa 2006 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
16339476 | Umesawa 2006 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | Smoking, EtOH
16339476 | Umesawa 2006 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Median Ca intake | No. of Cases (Event) * | Total N (person years) | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups *** | P for trend ****
MEN
16339476 | Umesawa 2006 | Total stroke death | Calcium intake quintile 1 | | 250 | 61 | 4623 | 8.9 y | Adjusted “multivariate” | RR | 1.0 | -- | -- | 0.13
| | | quintile 2 | | 363 | 76 | 4624 | | | | 1.14 | 0.76, 1.70 | NS
| | | quintile 3 | | 449 | 69 | 4623 | | | | 0.90 | 0.56, 1.45 | NS
| | | quintile 4 | | 536 | 59 | 4624 | | | | 0.69 | 0.40, 1.18 | NS
| | | quintile 5 | | 665 | 57 | 4623 | | | | 0.68 | 0.37, 1.26 | NS
WOMEN
16339476 | Umesawa 2006 | Total stroke death | Calcium intake quintile 1 | | 266 | 70 | 7121 | 8.9 y | Adjusted “multivariate” | RR | 1.0 | -- | -- | .01
| | | quintile 2 | | 379 | 82 | 7122 | | | | 1.38 | 0.95, 2.01 | NS
| | | quintile 3 | | 462 | 73 | 7122 | | | | 1.24 | 0.79, 1.95 | NS
| | | quintile 4 | | 545 | 42 | 7122 | | | | 0.69 | 0.40, 1.18 | NS
| | | quintile 5 | | 667 | 55 | 7122 | | | | 0.94 | 0.51, 1.72 | NS
MEN
16339476 | Umesawa 2006 | CHD death | Calcium intake quintile 1 | | 250 | 37 | 4623 | 8.9 y | Adjusted “multivariate” | RR | 1.0 | -- | -- | 0.43
| | | quintile 2 | | 363 | 26 | 4624 | | | | 0.84 | 0.47, 1.50 | NS
| | | quintile 3 | | 449 | 33 | 4623 | | | | 1.20 | 0.62, 2.30 | NS
| | | quintile 4 | | 536 | 32 | 4624 | | | | 1.27 | 0.60, 2.68 | NS
| | | quintile 5 | | 665 | 20 | 4623 | | | | 0.92 | 0.37, 2.29 | NS
WOMEN
16339476 | Umesawa 2006 | CHD death | Calcium intake quintile 1 | | 266 | 38 | 7121 | 8.9 y | Adjusted “multivariate” | RR | 1.0 | -- | -- | 0.50
| | | quintile 2 | | 379 | 21 | 7122 | | | | 0.88 | 0.48, 1.62 | NS
| | | quintile 3 | | 462 | 25 | 7122 | | | | 1.28 | 0.62, 2.61 | NS
| | | quintile 4 | | 545 | 17 | 7122 | | | | 0.84 | 0.35, 2.02 | NS
| | | quintile 5 | | 667 | 15 | 7122 | | | | 0.87 | 0.31, 2.45 | NS
MEN
16339476 | Umesawa 2006 | CVD death | Calcium intake quintile 1 | | 250 | 140 | 4623 | 8.9 y | Adjusted “multivariate” | RR | 1.0 | -- | -- | 0.95
| | | quintile 2 | | 363 | 141 | 4624 | | | | 0.98 | 0.75, 1.30 | NS
| | | quintile 3 | | 449 | 135 | 4623 | | | | 0.93 | 0.67, 1.29 | NS
| | | quintile 4 | | 536 | 135 | 4624 | | | | 0.92 | 0.64, 1.32 | NS
| | | quintile 5 | | 665 | 134 | 4623 | | | | 0.97 | 0.64, 1.48 | NS
WOMEN
16339476 | Umesawa 2006 | CVD death | Calcium intake quintile 1 | | 266 | 153 | 7121 | 8.9 y | Adjusted “multivariate” | RR | 1.0 | -- | -- | 0.14
| | | quintile 2 | | 379 | 156 | 7122 | | | | 1.29 | 0.99, 1.67 | NS
| | | quintile 3 | | 462 | 136 | 7122 | | | | 1.24 | 0.90, 1.69 | NS
| | | quintile 4 | | 545 | 98 | 7122 | | | | 0.92 | 0.64, 1.34 | NS
| | | quintile 5 | | 667 | 101 | 7122 | | | | 1.14 | 0.74, 1.74 | NS

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = -6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
16339476 | Umesawa 2006 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | nd | a) Method reported? (y/n) Y | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y # | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | N ## | a) Prospective collection of data? (y/n) | Y
| | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y # | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | ?
| | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n | N
OVERALL Grade (A/B/C): | | | | | | | A (B for total CVD mortality)
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Definition of CVD mortality implied only

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

# Median only

## CVD

## Umesawa 2008

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
18635855 | Umesawa 2008 | Cohort Study | 40-59 y | MI, angina, stroke, cancer at baseline | 1990 | Japan Public Health Center (JPHC)–based study (cohort I) | Gov’t | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake...etc.)
18635855 | Umesawa 2008 | Cohort Study | 4 areas Japan Okinawa (24°) to Akita (40°) | 41,526 | 41,526 | ~49 (nd) | 40–59 | 48% | Japanese | ~23.5 | Healthy | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data…etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
18635855 | Umesawa 2008 | Dietary calcium intake | FFQ | nd | Yes Spearman rank correlation coefficient 0.41 | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
18635855 | Umesawa 2008 | 1° | Stroke incidence (also stroke subtypes) | Participant reporting and hospital medical record review (National Survey of Stroke criteria)
18635855 | Umesawa 2008 | 1° | Fatal stroke | Death certificates & medical records
18635855 | Umesawa 2008 | 2° | Coronary heart disease | MI, sudden cardiac death, per participant reporting and medical record review (standard criteria)

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
18635855 | Umesawa 2008 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes | Na intake, K intake, n-3 fa intake
18635855 | Umesawa 2008 | Demographics (e.g., age, gender, race, education)? | Yes | Age, sex
18635855 | Umesawa 2008 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI
18635855 | Umesawa 2008 | Medical conditions | Yes | DM, HTN
18635855 | Umesawa 2008 | Medication | Yes | for hypercholesterolemia
18635855 | Umesawa 2008 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
18635855 | Umesawa 2008 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | Smoking, EtOH
18635855 | Umesawa 2008 | Other | Yes | Menopause

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Median Ca intake | No. of Cases (Event) * | N (Person- yr) | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups *** | P for trend ****
18635855 | Umesawa 2008 | Total stroke | Ca intake Quintile 1 | | 233 | 314 | ~8305 (112,018) | 13 y | Adjusted (“multivariable+HTN) | HR | 1.00 | -- | -- | .02
| | | Quintile 2 | | 344 | 257 | ~8305 (106,354) | | | | 0.94 | 0.79, 1.13 | NS
| | | Quintile 3 | | 439 | 252 | ~8305 (106,435) | | | | 0.79 | 0.65, 0.97 | <0.05
| | | Quintile 4 | | 603 | 247 | ~8305 (104,697) | | | | 0.78 | 0.63, 0.96 | <0.05
| | | Quintile 5 | | 753 | 251 | ~8305 (104,186) | | | | 0.71 | 0.56, 0.89 | <0.05
18635855 | Umesawa 2008 | CHD | Ca intake Quintile 1 | | 233 | 72 | ~8305 (112,018) | | Adjusted (“multivariable+HTN) | HR | 1.00 | -- | -- | NS
| | | Quintile 2 | | 344 | 72 | ~8305 (106,354) | | | | 1.18 | 0.83, 1.68 | NS
| | | Quintile 3 | | 439 | 56 | ~8305 (106,435) | | | | 0.91 | 0.60, 1.37 | NS
| | | Quintile 4 | | 603 | 58 | ~8305 (104,697) | | | | 1.08 | 0.71, 1.65 | NS
| | | Quintile 5 | | 753 | 64 | ~8305 (104,186) | | | | 0.93 | 0.58, 1.50 | NS

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
18635855 | Umesawa 2008 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | nd | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
18635855 | Umesawa 2008 | b) Sampling of population random or consecutive ? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed (y/n) | ?
18635855 | Umesawa 2008 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Y | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | A
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Well conducted. Generally well reported.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Van Beresteyn 1986

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
3788835 | Van Beresteyn 1986 | RCT | Female dietetic students 20–23 yrs of age, 49–76 kg bodyweight, not receiving any medical treatment at time of recruitment | nd | nd | Nd | Netherlands Institute for Dairy Research | KP

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
3788835 | Van Beresteyn | RCT | Netherlands (52°N) | 58 | 58 | 21(1.0) | 20–23 | 0% | Nd | Bodyweight = 49–76 kg | Nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
3788835 | Van Beresteyn | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | Nd | Nd | Nd | Nd | nd
| | Dietary calcium intake | Specially developed questionnaire (CIVO/TNO Department for Toxicology and Nutrition, Zeist, The Netherlands) | Dutch computerized food composition table | N | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
3788835 | Van Beresteyn | Calcium | Calcium powder containing calcium carbonate, citric acid, sodium-hydrogen carbonate, dextrose, and corn flour. Powders were consumed with lemonade or apple juice. | 1500 mg Ca++ | 6 weeks | Three times a day
| | placebo | Placebo powder containing citric acid, sodium-hydrogen carbonate, dextrose, and corn flour. Powders were consumed with lemonade or apple juice. | 0 mg Ca++ | 6 weeks | Three times a day
Co-intervention(s) * : | | | NA
Compliance/Adherence: | | | nd

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
3788835 | Van Beresteyn | Secondary | Body weight | Body weight in kg

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
3788835 | Van Beresteyn | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
3788835 | Van Beresteyn | Demographics (e.g., age, gender, race, education)? | No
3788835 | Van Beresteyn | Anthropometrics (e.g., BMI, body weight, % body fat)? | no
3788835 | Van Beresteyn | Medical conditions
3788835 | Van Beresteyn | Medication
3788835 | Van Beresteyn | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
3788835 | Van Beresteyn | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no
3788835 | Van Beresteyn | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline CI/SE/SD * | Final or Delta ** | Final or Delta CI/SE/SD * | Net difference | Net difference CI/SE/SD * | P between
3788835 | Van Beresteyn | Body weight | Kg | Calcium | 6 weeks | 29 | 61.8 | SD = 6.9 | Final = 61.5 | Final SD = 6.4 | 0.8 | Nd | Not significant
3788835 | Van Beresteyn | Body weight | Kg | placebo | 6 weeks | 29 | 62.5 | SD = 6.9 | Final = 63.0 | Final SD = 6.6
| | BMI | Kg/m ^ 2 ^ | Calcium | 6 weeks | 29 | 20.8 | SD = 2.0 | Final = 20.7 | Final SD = 1.9 | 0.2 | Nd | Not significant
| | BMI | Kg/m ^ 2 ^ | placebo | 6 weeks | 29 | 21.0 | SD = 1.9 | Final = 21.1 | Final SD = 1.8

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
3788835 | Van Beresteyn | RCT-parallel | nd | nd | nd | Y | nd | nd | Y | N | Y | B
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | No information on blinding, dropouts (or lack thereof)

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Van der Pols 2007

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
18065592 | van der Pols 2007 | Cohort study | Residence in England and Scotland | Subjects could not identified through the National Health Service Central Register, censored before 1948, lost to follow-up | 1937–1939 | The Boyd Orr cohort | The World Cancer Research Fund, The National Health and Medical Research Council of Australia | JHL

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
18065592 | van der Pols 2007 | Cohort study | England (54° N) Scotland (55° 57′ N) | 1343 families | 4374 children | 7.6 (sd, nd) | 4–11 yr | 49.5% | nd | Height z score: −0.01 BMI z score: 0.01 | nd | Nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
18065592 | van der Pols 2007 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | nd | nd | nd | nd
18065592 | van der Pols 2007 | Dietary calcium intake | 7-d household inventory method | Diet in, data-out program (DIDO software; Medical Research Council Human Nutrition Research Center, Cambridge, United Kingdom), Fruit and vegetable consumption (McCance and Widdowson’s The Composition of Foods) Prewar food tables were used to adapt the database if the composition of 1930s foods was very different from that of foods today, or if there was no modern-day equivalent. | nd | | | | | Ca 547.82 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
18065592 | van der Pols 2007 | nd | Colorectal cancer | Derived from the presence of a cancer code anywhere on the death certificate or from the first cancer that was registered.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
18065592 | van der Pols 2007 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Energy, fruit intakes
18065592 | van der Pols 2007 | Demographics (e.g., age, gender, race, education)? | Yes * - age, gender
18065592 | van der Pols 2007 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes/no *
18065592 | van der Pols 2007 | Medical conditions
18065592 | van der Pols 2007 | Medication
18065592 | van der Pols 2007 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
18065592 | van der Pols 2007 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes/no *
18065592 | van der Pols 2007 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
18065592 | van der Pols 2007 | Colorectal cancer | Ca intake did not have a clear independent association with colorectal cancer risk in this population (multivariate adjusted OR for highest vs. lowest intake: 1.91; 95% CI: 0.84. 4.32; P for trend=0.18) CRC cases =76

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
18065592 | van der Pols 2007 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | N | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | N | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | N | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
18065592 | van der Pols 2007 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | N | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | N | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | N | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
18065592 | van der Pols 2007 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | NA | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | N | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Per capita food and nutrient intake were calculated by dividing daily total intake by the total number of household members. Childhood diet was based on household rather than individual consumption. 7 day diet inventory instead of FFQ; cases not confirmed by histology reports blinding not reported; power calculation not reported; blinding not reported

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Van der Vijver 1992

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
1544755 | van der Vijver 1992 | Cohort study | Civil servants or spouses 40–65 yo | nd on survival or cause of death, Ca intake, men <1500 Kcal/day, women <1250 Kcal/day | 1953–54 | Dutch civil servants | Heart foundation | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
1544755 | van der Vijver 1992 | Cohort study | Amsterdam, Netherlands 52° | 2925 (incl those with nd) | 2605 | 52 | 40–65 | 51% | White (implied) | Men 24.6 Women 26.3 | All | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
1544755 | van der Vijver 1992 | Dietary calcium intake | 1 week FFQ | Dutch Food Composition Tables | N | | | | | Ca intake Men 928±413 mg Women 660±283 mg

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
1544755 | van der Vijver 1992 | 1° | CVD mortality | Death certificates, national records of cause of death ICD codes
1544755 | van der Vijver 1992 | 1° | CHD mortality | same
1544755 | van der Vijver 1992 | 2° | All cause mortality | same

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
1544755 | van der Vijver 1992 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
1544755 | van der Vijver 1992 | Demographics (e.g., age, gender, race, education)? | Yes | Age
1544755 | van der Vijver 1992 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI
1544755 | van der Vijver 1992 | Medical conditions
1544755 | van der Vijver 1992 | Medication
1544755 | van der Vijver 1992 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
1544755 | van der Vijver 1992 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | smoking, EtOH
1544755 | van der Vijver 1992 | Other | Yes | SBP, cholesterol

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Follow-up | Mean Ca level/dose | No. of Cases (Event) * | Total N | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups *** | P for trend ****
1544755 | van der Vijver 1992 | All cause mortality, men | Quintile 1 | 28 y | ≤585 | nd | 271 | Adjusted | OR | 1.1 | 0.7–1.5 | NS
| | | Quintiles 2–4 | | 585–1245 | nd | 798 | | | 0.9 | 0.7–1.2 | NS
| | | Quintile 5 | | >1245 | nd | 271 | | | 1.0 | --
| | All cause mortality, women | Quintile 1 | 28 y | ≤445 | nd | 258 | Adjusted | OR | 1.3 | 0.8–2.0 | NS
| | | Quintiles 2–4 | | 445–850 | nd | 750 | | | 1.2 | 0.8–1.8 | NS
| | | Quintile 5 | | >850 | nd | 257 | | | 1.0 | --
| | CVD mortality, men | Quintile 1 | 28 y | ≤585 | 31.9% (age adj) | 271 | Adjusted | OR | 1.3 | 0.8–1.9 | NS
| | | Quintiles 2–4 | | 585–1245 | 26.7% | 798 | | | 1.1 | 0.8–1.5 | NS
| | | Quintile 5 | | >1245 | 24.9% | 271 | | | 1.0 | --
| | CVD mortality, women | Quintile 1 | 28 y | ≤445 | 14.6% (age adj) | 258 | Adjusted | OR | 1.1 | 0.6–2.0 | NS
| | | Quintiles 2–4 | | 445–850 | 14.4% | 750 | | | 1.1 | 0.7–1.7 | NS
| | | Quintile 5 | | >850 | 12.6% | 257 | | | 1.0 | --
| | CHD mortality, men | Quintile 1 | 28 y | ≤585 | 16.6% (age adj) | 271 | Adjusted | OR | 0.9 | 0.6–1.6 | NS
| | | Quintiles 2–4 | | 585–1245 | 15.1% | 798 | | | 1.0 | 0.6–1.5 | NS
| | | Quintile 5 | | >1245 | 14.5% | 271 | | | 1.0 | --
| | CHD mortality, women | Quintile 1 | 28 y | ≤445 | 6.2% (age adj) | 258 | Adjusted | OR | 1.1 | 0.5–2.5 | NS
| | | Quintiles 2–4 | | 445–850 | 6.3% | 750 | | | 1.2 | 0.6–2.3 | NS
| | | Quintile 5 | | >850 | 4.4% | 257 | | | 1.0 | --

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
1544755 | van der Vijver 1992 | Same outcomes | Similar results at 15 y follow-up, results not shown.

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
1544755 | van der Vijver 1992 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | nd | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
1544755 | van der Vijver 1992 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | ?
1544755 | van der Vijver 1992 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | | Analyses simplistic. More complete analyses were not performed.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Visser 2006

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
16960177 | Visser 2006 | Cohort study (posthoc) | representative Dutch older population (≥65 y); born before 1930; has blood sample | not living independently; no blood sample; missing contact information | 1996 | Longitudinal Aging Study Amsterdam | government | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
16960177 | Visser 2006 | Cohort study | W, NE, S of the Netherlands | 1260 | 1260 | ≥65 y | 65 to ≥80 y | 51 | nd | BMI <25 to ≥30 | 31–41% with CVD; 44–59% with arthritis | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
16960177 | Visser 2006 | 25(OH)D | | | | Competitive protein-binding (Nichols Diagnostics, CA) | Y interassay CV <15% | 1–2 y | nd | nd
| | Dietary calcium intake

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
16960177 | Visser 2006 | primary | mortality | by death certificate

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
16960177 | Visser 2006 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
16960177 | Visser 2006 | Demographics (e.g., age, gender, race, education)? | Yes * age, sex, education
16960177 | Visser 2006 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes/no *
16960177 | Visser 2006 | Medical conditions
16960177 | Visser 2006 | Medication
16960177 | Visser 2006 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location)
16960177 | Visser 2006 | Smoking and other life styles variables | Yes * frailty indicators and lifestyle variables
16960177 | Visser 2006 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | Result | 95% CI | P btw
16960177 | Visser 2006 | mortality
16960177 | Visser 2006 | mortality

* Example: OR Ca/placebo

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of cases (events) * | Total N | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
16960177 | Visser 2006 | mortality | published cutoffs 25(OH)D | <25 nmol/L | | 66 | 127 | adjusted for sex, age, education | HR | 1.61 | 1.09–2.37 | | 0.0058
| | | | 25–49.9 | | 42 | 462 | | | 1.17 | 0.85–1.62
| | | | 50–74.9 | | 30 | 440 | | | 0.93 | 0.67–1.29
| | | | ≥75 | | 29 | 231 | | | 1.0
16960177 | Visser 2006 | mortality | published cutoffs 25(OH)D | <25 | | 66 | 127 | adjusted for above plus chronic diseases, serum creatinine, cognition, depressive symptoms | | 1.54 | 1.04–2.29 | | 0.021
| | | | 25–49.9 | | 42 | 462 | | | 1.11 | 0.80–1.54
| | | | 50–74.9 | | 30 | 440 | | | 0.95 | 0.68–1.32
| | | | ≥75 | | 29 | 231 | | | 1.0
16960177 | Visser 2006 | mortality | published cutoffs 25(OH)D | <25 | | 66 | 127 | adjusted for above plus lifestyle variables | | 1.47 | 0.99–2.19 | | 0.046
| | | | 25–49.9 | | 42 | 462 | | | 1.08 | 0.78–1.51
| | | | 50–74.9 | | 30 | 440 | | | 0.95 | 0.68–1.32
| | | | ≥75 | | 29 | 231 | | | 1.0
16960177 | Visser 2006 | mortality | published cutoffs 25(OH)D | <25 | | 66 | 127 | adjusted for above plus frailty indicators | | 1.28 | 0.85–1.92 | | 0.19
| | | | 25–49.9 | | 42 | 462 | | 1.00 | 0.72–1.40
| | | | 50–74.9 | | 30 | 440 | | 0.91 | 0.65–1.26
| | | | ≥75 | | 29 | 231 | | 1.0

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
16960177 | Visser 2006 | mortality | association did not differ significantly between men and women or between subjects aged <70, 70–79, and≥80 y (P>0.33); subjects who were excluded from this study were more likely to die (59.4%) than the ones included (30.2%).

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
16960177 | Visser 2006 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | N | a) Method reported? (y/n) | N | a) One of the prespecified methods was used? (y/n) | N | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | N
16960177 | Visser 2006 | b) Sampling of population random or consecutive? (y/n) | N | b) Outcome assessor blinded to exposure measurement? (y/n) | N | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | Y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
16960177 | Visser 2006 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | NA | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | posthoc analysis; reported results are likely biased because selected only subjects with available blood sample and subjects who were excluded from this study were more likely to die than the ones included

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

## Wactawski-Wende 2006 and Ding 2008

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
16481636 | Wactawski-Wende 2006 | 1. RCT (for supplement part of study) 2. Case- cohort *** | RCT part:; - Postmenopausal women (aged 50–79) (n=36282)Case-cohort part:; - Cases: invasive colorectal cancer (n=317; although 322 cases were found in the entire study...); - Controls: 1:1 matching colorectal cancer free participants by age, center, race, ethnic group (n=317) | RCT part:; - Predicted survival of less than three 3years; - a history of renal calculi or hypercalcemia; - current use of oral corticosteroids; - current daily use of at least 600IU of supplemental vitamin D or calcitriol; Case-cohort part: Cases: carcinoma in situ and primary cancers of other sites Inadequate serum (11 pairs [cases+controls]) | 1993–1998 (after 1- year run-in period followed, patients were randomized in between 1995–2000) | 1. Women’s Health Initiative randomized trials 2. Ca+VitD supplementation trial | NHLBI, DHHS | JHL/TTe
18092326 | Ding 2008 | RCT | | | 1993–1998 (after 1- year run-in period followed, patients were randomized in between 1995–2000) | 1. Women’s Health Initiative randomized trials 2. Ca+VitD supplementation trial | NHLBI, DHHS | JHL/TTe

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

*** After a review of initial findings, a nested case-control study was proposed to determine whether the serum 25-hydroxyvitaminD level at baseline modified the outcome.

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
16481636 | Wactawski- Wende 2006 | 1. RCT (for supplement part of study) 2. Case- cohort | US (38ºN) | RCT part: 36282 (Ca+vitD supplements n=18176, placebo n=18106) Case-cohort part: 634 (cases n=317, controls n=317) | RCT part: 36282 Case- cohort part: 612 (cases n=306, controls n=306) | nd | 50–79y | 0% | White 83.1% Black 9.1% Hispanic 4.2% Indian/Alaskan Native 0.4% Asian or Pacific Islander 2.0% Unknown 1.2% | nd | Previous polyps: 8% Family Hx: 15% Aspirin: 19.4% HRT: 68.3% Participants of other trials: WHI hormone therapy trial: 56% WHI dietary modification trial: 31% | nd
18092326 | Ding 2008 | RCT | US (38ºN) | RCT part: 36282 (Ca+vitD supplements n=18176, placebo n=18106) Case-cohort part: 634 (cases n=317, controls n=317) | N=16089 | nd | 50–79y | 0% | White 83.1% Black 9.1% Hispanic 4.2% Indian/Alaskan Native 0.4% Asian or Pacific Islander 2.0% Unknown 1.2% | nd | Previous polyps: 8% Family Hx: 15% Aspirin: 19.4% HRT: 68.3% Participants of other trials: WHI hormone therapy trial: 56% WHI dietary modification trial: 31% | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data ...etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
16481636 18092326 | Wactawski- Wende 2006 Ding 2008 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | RIA | Y, interassay coefficient of variation=11.8% | nd | nd | nd
16481636 18092326 | Wactawski- Wende 2006 Ding 2008 | Dietary calcium intake | nd | nd | nd | | | | | Ca (supplements+diet) <800mg/d(%)=34 800- <1200mg/d(%)=26.3 ≥1200mg/d(%)=39.6

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
16481636 18092326 | Wactawski- Wende 2006 Ding 2008 | VitD+Ca | VitD–GlaxoSmithKline Ca–calcium carbonate | VitD 400 IU Ca 1000 mg | 7y | 200IU of VitD twice daily 500mg of Ca twice daily
| | placebo | “identical appearing placebo tablet” | NA | 7y | Taken twice daily
Co-intervention(s) * : | | | 54% of the participants enrolled in the trial of dietary modification, 69% enrolled in the trial of dietary modification and 14%
Compliance/Adherence: | | | participated in the both trials. During year 1, 60% of the participants took at least 80% of their study medication, and this % remained stable through year 6, with small differences between groups. At least 70 % took 50% or more of their study medication through year 6.

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
16481636 & 18092326 | Wactawski-Wende 2006 & Ding 2008 | Secondary (primary: hip fracture) | (Invasive) colorectal cancer | Verified in a blinded fashion and coded with the use of the surveillance, epidemiology, and end results system; 99.4% of reported cancers were centrally confirmed. A total of 339 colorectal cancers. Of these, 9 were in situ and 8 were primary cancers of other sites. (Excluded in situ and primary cancers of other sites)
16481636 | Wactawski-Wende 2006 | nd | (Invasive) colon cancer | Excluded in situ and primary cancers of other sites
16481636 | Wactawski-Wende 2006 | nd | (invasive) rectal cancer | Excluded in situ and primary cancers of other sites
16481636 | Wactawski-Wende 2006 | nd | All cause mortality | nd
16481636 | Wactawski-Wende 2006 | nd | Death from colorectal cancer | Death from colorectal cancer
16481636 | Wactawski-Wende 2006 | nd | Intestinal polyps | Intestinal polyps based on participants’ self-report not centrally verified.
16481636 | Wactawski-Wende 2006 | nd | Kidney stone | Kidney stone based on participants’ self-report not centrally verified.
16481636 | Wactawski-Wende 2006 | nd | Total cancer incidence | Intestinal polyps based on participants’ self-report not centrally verified.
16481636 | Wactawski-Wende 2006 | nd | Cancer related mortality | Kidney stone based on participants’ self-report not centrally verified.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
16481636 18092326 | Wactawski- Wende 2006 Ding 2008 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | | No significant interactions were found with any baseline characteristic examined. ([Shown in Figure 1] Baseline characteristics: age at screening, race or ethnic group, education, first-degree relative with colorectal cancer, history of poly removal, BMI, physical activity, total energy intake, energy from saturated fat, total calcium intake, total vitD intake, region according to solar irradiance, multivitamin use, smoking status, NSAID use, hormone therapy use, enrollment in WHI hormone therapy trials, enrollment in WHI dietary modification trail)
16481636 18092326 | Wactawski- Wende 2006 Ding 2008 | Demographics (e.g., age, gender, race, education)? | Yes (age)
16481636 18092326 | Wactawski- Wende 2006 Ding 2008 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes
16481636 18092326 | Wactawski- Wende 2006 Ding 2008 | Medical conditions | History of colorectal cancer
16481636 18092326 | Wactawski- Wende 2006 Ding 2008 | Medication
16481636 18092326 | Wactawski- Wende 2006 Ding 2008 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
16481636 18092326 | Wactawski- Wende 2006 Ding 2008 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes
16481636 18092326 | Wactawski- Wende 2006 Ding 2008 | Other | Clinical center

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | Result | 95% CI | P btw
16481636 | Wactawski- Wende 2006 | Invasive colorectal cancer | VitD 400 IU + Ca 1000 mg | 84 | 168 | 18176 | HR Vit D+Ca/placebo | | | | 1.08 | 0.86–1.34 | 0.51
16481636 | Wactawski- Wende 2006 | Invasive colorectal cancer | Placebo | 84 | 154 | 18106 | HR Vit D+Ca/placebo | | | | 1.08 | 0.86–1.34 | 0.51
16481636 | Wactawski- Wende 2006 | Invasive colon cancer | VitD 400 IU + Ca 1000 mg | 84 | 128 | 18176 | HR Vit D+Ca/placebo | | | | 1.00 | 0.78–1.28 | 0.99
16481636 | Wactawski- Wende 2006 | Invasive colon cancer | Placebo | 84 | 126 | 18106 | HR Vit D+Ca/placebo | | | | 1.00 | 0.78–1.28 | 0.99
16481636 | Wactawski- Wende 2006 | Invasive rectal cancer | VitD 400 IU + Ca 1000 mg | 84 | 44 | 18176 | HR Vit D+Ca/placebo | | | | 1.46 | 0.92–2.32 | 0.11
16481636 | Wactawski- Wende 2006 | Invasive rectal cancer | Placebo | 84 | 30 | 18106 | HR Vit D+Ca/placebo | | | | 1.46 | 0.92–2.32 | 0.11
16481636 | Wactawski- Wende 2006 | Death from colorectal cancer | VitD 400 IU + Ca 1000 mg | 84 | 34 | 18176 | HR Vit D+Ca/placebo | | | | 0.82 | 0.52–1.29 | 0.39
16481636 | Wactawski- Wende 2006 | Death from colorectal cancer | Placebo | 84 | 41 | 18106 | HR Vit D+Ca/placebo | | | | 0.82 | 0.52–1.29 | 0.39
16481636 | Wactawski- Wende 2006 | All cause mortality | VitD 400 IU + Ca 1000 mg | 84 | 744 | 18176 | HR Vit D+Ca/placebo | | | | 0.91 | 0.83–1.01 | 0.07
16481636 | Wactawski- Wende 2006 | All cause mortality | Placebo | 84 | 807 | 18106 | HR Vit D+Ca/placebo | | | | 0.91 | 0.83–1.01 | 0.07
16481636 | Wactawski- Wende 2006 | Total cancer | VitD 400 IU + Ca 1000 mg | 84 | 1634 | 18176 | HR Vit D+Ca/placebo | | | | 0.98 | 0.91–1.05 | 0.53
16481636 | Wactawski- Wende 2006 | Total cancer | Placebo | 84 | 1655 | 18106 | HR Vit D+Ca/placebo | | | | 0.98 | 0.91–1.05 | 0.53
16481636 | Wactawski- Wende 2006 | Cancer mortality | VitD 400 IU + Ca 1000 mg | 84 | 344 | 18176 | HR Vit D+Ca/placebo | | | | 0.89 | 0.77–1.03 | 0.12
16481636 | Wactawski- Wende 2006 | Cancer mortality | Placebo | 84 | 382 | 18106 | HR Vit D+Ca/placebo | | | | 0.89 | 0.77–1.03 | 0.12
16481636 | Wactawski- Wende 2006 | Kidney stone (UL) | VitD 400 IU + Ca 1000 mg | 84 | 449 | 18176 | HR Vit D+Ca/placebo | | | | 1.17 | 1.02–1.34 | 0.02
16481636 | Wactawski- Wende 2006 | Kidney stone (UL) | Placebo | 84 | 381 | 18106 | HR Vit D+Ca/placebo | | | | 1.17 | 1.02–1.34 | 0.02
16481636 | Wactawski- Wende 2006 | Intestinal Polyp | VitD 400 IU + Ca 1000 mg | 84 | 2983 | 18176 | HR Vit D+Ca/placebo | | | | 0.99 | 0.94–1.04 | 0.71
16481636 | Wactawski- Wende 2006 | Intestinal Polyp | Placebo | 84 | 2997 | 18106 | HR Vit D+Ca/placebo | | | | 0.99 | 0.94–1.04 | 0.71

* Example: OR Ca/placebo

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
18092326 | Ding 2008 | Colorectal cancer | While Ca + vitamin D supplementation among women concurrently assigned to estrogen therapies suggested increased risk (HR=1.5, 95% CI: 0.96, 2.33), among women concurrently assigned to placebo arms of the estrogen trials, Ca + vitamin D indicated suggestive benefits (HR=0.71, 95% CI=0.46–1.09) (p-for-estrogen-interaction=0.018)

Nested Case-Control study

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | No. of Non- cases ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups*** | P for trend****
16481636 | Wactawski- Wende 2006 | Invasive colorectal cancer | 25- hydroxyvitaminD group 1 | ≥58.4nmol/liter | | 60 | 93 | Adjusted | OR | 1.00 | | | 0.02
| | | 25- hydroxyvitaminD group 2 | 42.4–58.3nmol/liter | | 78 | 73 | Adjusted | OR | 1.96 | 1.18–3.24
| | | 25- hydroxyvitaminD group 3 | 31.0–42.3nmol/liter | | 80 | 73 | Adjusted | OR | 1.95 | 1.18–3.24
| | | 25- hydroxyvitaminD group 4 | <31.0nmol/liter | | 88 | 67 | Adjusted | OR | 2.53 | 1.49–4.32

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
16481636 | Wactawski- Wende 2006 | RCT- parallel | Y | Y | NA | Y | Y | Y | Y | Y | Y | B
Adverse Event(s): ** | | | | | | Kidney stones
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Original study was designed for assessing the risks and benefits of hormone therapy and dietary modification. At the time the study ended, 352 women assigned to calcium with vitamin D supplements and 332 women assigned to placebo had withdrawn; 144 and 152, respectively, had been lost to follow-up. This study was downgraded to B because there are very serious problems with WHI as a study reporting no association of Ca+D on endpoints. The most prominent problem with the trial as evidence for no association for Ca+D is the poor compliance with study treatment. Another serious problem is the allowance in the trial of use of supplements. The trial is a B when reporting no association because non-compliance and the “contamination” of the non-intervention group would cause bias to the null. It was the consensus among the Tufts EPC that overall, the methodological quality of the trial was B, particularly when the trial is being used to guide decisions about DRI, as opposed to decisions about whether to actively recommend supplementation for an individual woman.

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
18092326 | Ding 2008 | RCT- parallel | Y | Y | NA | Y | Y | Y | Y | Y | Y | B
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | The reduced sample size (<50%) of the original WHI power calculations assuming no interaction with estrogen therapies It was the consensus among the Tufts EPC that overall, the methodological quality of the trial was B, particularly when the trial is being used to guide decisions about DRI, as opposed to decisions about whether to actively recommend supplementation for an individual woman.

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

QUALITY OF COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | Exposure (All) | Dietary assessment * | Biomarkers * | Comparator | Statistical Analysis | Outcome | Design
| | a) Eligibility criteria clear? (y/n) | a) Exposure assessor blinded to outcome info? (y/n) | a) Method reported? (y/n) | a) One of the prespecified methods *** was used? (y/n) | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | a) Clear definition of outcome, including time of ascertainment? (y/n) | a) Prospective collection of data? (y/n)
| | b) Sampling of population random or consecutive? (y/n) | b) Outcome assessor blinded to exposure measurement? (y/n) | b) Food composition database or suppl composition reported? (y/n) | Time from sample collection to sample analysis reported? (y/n) | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | b) Loss to follow-up <20%? (y/n) | b) Analysis was planned when cohort was formed? (y/n)
| | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | | | b) Justification of final adjusted model selection? (y/n) | c) Do the authors specify a primary outcome? (y/n) | c) Justification of sample size (includes sample size calculations)? (y/n)
OVERALL Grade (A/B/C):
Explanation for Overall Quality Grade (if not Grade A):

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Wagner 2006

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17661565 | Wagner 2006 | RCT | Fully lactating mothers within 1 mo postpartum | DM; HTN; parathyroid disease; uncontrolled thyroid disease | nd | - | academic; NIH | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake...etc.)
17661565 | Wagner 2006 | RCT | Charleston, SC 32°47′N | 19 | 19 | 29 | | 0 | 89% white | | | dietary calcium intake: 1125 mg/d; dietary vit D 273 IU/d

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data…etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
17661565 | Wagner 2006 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | RIA | n | | | dietary vit D 273 IU/d
17661565 | Wagner 2006 | Dietary calcium intake | Block 1998.2 FFQ | | n | | | | | calcium intake: 1125 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
17661565 | Wagner 2006 | | United Research Labs, PA RXChoice®, NY | mom: 400 IU vit D3 infant: 300 IU vit D3/d | 6 mo | one prenatal vitamin and two placebo study tablets qd
17661565 | Wagner 2006 | | United Research Labs, PA; Tishcon Corp., NY | mom: 400 IU + 6000 IU vit D3 infant: placebo drops | | one prenatal vitamin and two vitamin D study tablets qd
Co-intervention(s) * :
Compliance/Adherence: | | | ≥80% for mom; as low as 61% for infants

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17661565 | Wagner 2006 | primary | 25(OH)D level in mom
17661565 | Wagner 2006 | | vit D3 level in mom
17661565 | Wagner 2006 | | 25(OH)D level in infant
17661565 | Wagner 2006 | | anti-rachitic activity in milk | vit D3 and 25 (OH)D in milk converted into biological activity using reference data
17661565 | Wagner 2006 | | infant weight and length

UI | Author Year | Comments
17661565 | Wagner 2006 | subjects compensated with gift cards

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17661565 | Wagner 2006 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
17661565 | Wagner 2006 | Demographics (e.g., age, gender, race, education)? | Yes * | age, race
17661565 | Wagner 2006 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes * | changes in skin pigmentation
17661565 | Wagner 2006 | Medical conditions
17661565 | Wagner 2006 | Medication
17661565 | Wagner 2006 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
17661565 | Wagner 2006 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes * | outdoor activities
17661565 | Wagner 2006 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline CI/SE/SD * | Final or Delta ** | Final or Delta CI/SE/SD * | Net difference | Net difference CI/SE/SD * | P between
17661565 | Wagner 2006 | mom 25 (OH)D at 1 mo | ng/mL | mom 400 | | 10 | | | 32.2 | | | | nd
17661565 | Wagner 2006 | mom 25 (OH)D at 1 mo | ng/mL | mom 6400 | | 9 | | | 34
| | at 2 mo | | mom 400 | | 10 | | | 35.1
| | at 2 mo | | mom 6400 | | 9 | | | 47.1
| | at 3 mo | | mom 400 | | 10 | | | 35.1
| | at 3 mo | | mom 6400 | | 9 | | | 48.4
| | at 4 mo | | mom 400 | | 10 | | | 28.9
| | at 4 mo | | mom 6400 | | 9 | | | 45
| | at 5 mo | | mom 400 | | 10 | | | 25.9
| | at 5 mo | | mom 6400 | | 9 | | | 50.6
| | at 6 mo | | mom 400 | | 10 | | | 33.5
| | at 6 mo | | mom 6400 | | 9 | | | 51.9
| | at 7 mo | | mom 400 | | 10 | | | 38.4
| | at 7 mo | | mom 6400 | | 9 | | | 58.8
17661565 | Wagner 2006 | mom vit D3 level at 1 mo | ng/mL | mom 400 | | 10 | | | 2.2 | | | | nd
17661565 | Wagner 2006 | mom vit D3 level at 1 mo | ng/mL | mom 6400 | | 9 | | | 4.1
| | at 2 mo | | mom 400 | | 10 | | | 2.8
| | at 2 mo | | mom 6400 | | 9 | | | 30.3
| | at 3 mo | | mom 400 | | 10 | | | 3.5
| | at 3 mo | | mom 6400 | | 9 | | | 32.4
| | at 4 mo | | mom 400 | | 10 | | | 2.8
| | at 4 mo | | mom 6400 | | 9 | | | 39.2
| | at 5 mo | | mom 400 | | 10 | | | 3.7
| | | | mom 6400 | | 9 | | | 49.6
| | at 6 mo | | mom 400 | | 10 | | | 5.3
| | | | mom 6400 | | 9 | | | 43.9
| | at 7 mo | | mom 400 | | 10 | | | 4
| | | | mom 6400 | | 9 | | | 49.7
17661565 | Wagner 2006 | antirachitic activity in milk at 1 mo | IU | mom 400 | | 10 | | | 59.6 | | | | nd
| | | | mom 6400 | | 9 | | | 82.4
| | at 2 mo | | mom 400 | | 10 | | | 71.2
| | | | mom 6400 | | 9 | | | 387
| | at 3 mo | | mom 400 | | 10 | | | 78.6
| | | | mom 6400 | | 9 | | | 370.5
| | at 4 mo | | mom 400 | | 10 | | | 45.7
| | | | mom 6400 | | 9 | | | 374.4
| | at 5 mo | | mom 400 | | 10 | | | 68.3
| | | | mom 6400 | | 9 | | | 555.2
| | at 6 mo | | mom 400 | | 10 | | | 69.9
| | | | mom 6400 | | 9 | | | 624.5
| | at 7 mo | | mom 400 | | 10 | | | 76.3
| | | | mom 6400 | | 9 | | | 873.5 | | | | <0.0003
17661565 | Wagner 2006 | infant 25 (OH)D at 1 mo | ng/mL | infant 300 | | 10 | | | 13 | | | | nd
| | | | infant placebo | | 9 | | | 14
| | at 2 mo | | infant 300 | | 10 | | | 33
| | | | infant placebo | | 9 | | | 36
| | at 7 mo | | infant 300 | | 10 | | | 43
| | | | infant placebo | | 9 | | | 46
| | infant weight at 1 mo | Kg | infant 300 | | 10 | | | 4.7 | 0.4 | | | 0.80
| | | | infant placebo | | 9 | | | 4.6 | 0.7
| | at 4 mo | | infant 300 | | 10 | | | 6.7 | 0.5 | | | 0.91
| | | | infant placebo | | 9 | | | 6.6 | 0.8
| | at 7 mo | | infant 300 | | 10 | | | 7.6 | 0.8 | | | 0.30
| | | | infant placebo | | 9 | | | 8.4 | 1.1
| | infant length at 1 mo | cm | infant 300 | | 10 | | | 54.6 | 1.1 | | | 0.29
| | | | infant placebo | | 9 | | | 55.9 | 2.9
| | at 4 mo | | infant 300 | | 10 | | | 62.4 | 1.7 | | | 0.75
| | | | infant placebo | | 9 | | | 62.8 | 1.9
| | at 7 mo | | infant 300 | | 10 | | | 65.5 | 1.8 | | | 0.06
| | | | infant placebo | | 9 | | | 69.3 | 2.9

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
17661565 | Wagner 2006 | RCT | Y | Y | NA | Y | N | Y | N | N | N | C
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | pilot study, small sample size, details of analysis not reported; up to 39% of infants might not have received the intended intervention

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Wang 2008a

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
18259007 | Wang 2008 | Cohort Study | Women US health professionals, ≥45 y | CVD, Nonmelanoma cancer, insufficient completion of FFQ, implausible total energy intake (not defined), Baseline HTN (self reported MD diagnosis, SBP≥140, DBP≥90, or antihypertensive drug) | 1992–1995 | Women’s Health Study | Gov’t | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
18259007 | Wang 2008 | Cohort Study | US various | 28,886 | 28,886 | 53.8 (~6.5) | ≥45 y | 0% | ~94% white | ~25.1±~4.5 | Healthy | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data ...etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd
18259007 | Wang 2008 | Dietary calcium intake | FFQ | Harvard School of Public Health | No, but in “similar cohorts of health professionals” data provided | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
18259007 | Wang 2008 | 1° | Incident HTN | At least 1 of: self report of new physician diagnosis; self-report starting antihypertensive drug; self-report SBP≥140 mm Hg; self-report DBP≥90 mm Hg (censored on the date of CVD diagnosis)

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
18259007 | Wang 2008 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes | Total energy intake; fruit, vegetable, whole grain, red meat intake
18259007 | Wang 2008 | Demographics (e.g., age, gender, race, education)? | Yes | Age, Race
18259007 | Wang 2008 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI
18259007 | Wang 2008 | Medical conditions | Yes | DM, hypercholestolemia
18259007 | Wang 2008 | Medication | Yes | randomization to aspirin, vitamin E, multivitamin use
18259007 | Wang 2008 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
18259007 | Wang 2008 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | Smoking, EtOH, physical activity
18259007 | Wang 2008 | Other | | Menopausal status

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Median (range) Vit D dose | Median (range) Ca intake | No. of Cases (Event) * | Total N ** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups *** | P for trend ****
18259007 | Wang 2008 | Incident HTN | Dietary Calcium Quintile 1 | | 483.5 (189–557.9) | 1860 | 5777 | 10 y | Adjusted (“multivariate) | HR | 1.00 | -- | | <.0001
| | | Quintile 2 | | 620.4 (558–678.9) | 1778 | 5777 | | | | 0.96 | 0.90, 1.03 | NS
| | | Quintile 3 | | 739.6 (679–801.9) | 1626 | 5777 | | | | 0.89 | 0.83, 0.95 | <.05
| | | Quintile 4 | | 883.5 (802–999.9) | 1634 | 5777 | | | | 0.89 | 0.83, 0.95 | <.05
| | | Quintile 5 | | 1170.4 (1000–2559) | 1631 | 5777 | | | | 0.87 | 0.81, 0.93 | <.05
18259007 | Wang 2008 | Incident HTN | Supplement Vit D Quartile 1 | 0 (0) | | 5745 | nd | 10 y | Adjusted (“multivariate) | HR | 1.00 | --
| | | Quartile 2 | 228 (2–249) | | 951 | nd | | | | 1.00 | 0.93, 1.09 | NS
| | | Quartile 3 | 400 (250–399) | | 1648 | nd | | | | 1.03 | 0.96, 1.11 | NS
| | | Quartile 4 | 800 (400–2000) | | 185 | nd | | | | 1.09 | 0.93, 1.27 | NS | 0.27

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
18259007 | Wang 2008 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | nd | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
18259007 | Wang 2008 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | ?
18259007 | Wang 2008 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N # | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | | Calcium: A Vit D: C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | | Good methods and analysis of Calcium. Vitamin D analysis poorly described. Minor errors in text regarding methods for Vit D analysis. Report that vitamin D analyzed in 4 “quintiles” (sic), but bottom quintile is no vitamin D supplement and nd given on numbers of participants in each group.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

# Data reported for similar studies

## Wang 2008b

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
18180395 | Wang 2008 | Cohort study | Framingham Offspring 25(OH)D measured 1996–2000 | Prevalent CVD or CKD | 1996–2000 (originally 1971) | Framingham Offspring | nd | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
18180395 | Wang 2008 | Cohort study | Probably mostly still around Framingham, MA 42° | 1739 (Originally 5124) | 1739 | 59 (9) | nd | 45% | White 100% | BMI 28.1 | No CVD, CKD | Vit D supplement 4% Multivitamin 41%

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data ...etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
18180395 | Wang 2008 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | RIA (DiaSorin) | Yes CoV 8.5% (intraassay); 13.2% (interassay) | ≤3 yr | | nd
| | Dietary calcium intake

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
18180395 | Wang 2008 | Primary | First cardiovascular event | MI, coronary insufficiency, angina, stroke, TIA, claudication, heart failure (all defined per Framingham study criteria)

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
18180395 | Wang 2008 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes | Use of Vit D containing supplements
18180395 | Wang 2008 | Demographics (e.g., age, gender, race, education)? | Yes | Age, sex, education (<12 y)
18180395 | Wang 2008 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI
18180395 | Wang 2008 | Medical conditions | Yes | DM
18180395 | Wang 2008 | Medication | Yes | anti-HTNive
18180395 | Wang 2008 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | Yes | Season of blood draw Physical activity
18180395 | Wang 2008 | Smoking and other life styles variables | Yes | Smoking
18180395 | Wang 2008 | Other | Yes | SBP, TC/HDL, SCr, (CRP, analysis not included here)

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | Result | 95% CI | P btw
18180395 | Wang 2008 | CV event | 25(OH)D <15 ng/mL | 5.4 yr | 50 | 481 | Unadjusted: Rate (age and sex adjusted) Adjusted: HR | 8.9% | 5.5, 12.2 | nd | 1.70 | 1.08, 2.67 | .02
18180395 | Wang 2008 | CV event | 25(OH)D ≥15 ng/mL | | 70 | 1258 | Unadjusted: Rate (age and sex adjusted) Adjusted: HR | 4.4% | 2.8, 5.9 | nd | 1.70 | 1.08, 2.67 | .02

* Example: OR Ca/placebo

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non- cases/Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
18180395 | Wang 2008 | CV event | Severe deficiency | <10 ng/mL | | nd | nd | Adjusted † | HR | 1.80 | 1.05, 3.08 | <.05 | .01
| | | Deficiency | 10-<15 ng/mL | | nd | nd | Adjusted † | HR | 1.53 | 1.00, 2.36 | P=.05
| | | Referent | ≥15 ng/mL | | 70 | 1258 | Adjusted †

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

† Not adjusted for physical activity, vit D suppl, educational attainment, season.

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
18180395 | Wang 2008 | CV event | Multivariable Cox with continuous 25(OH)D and regression splines with nonlinear relationship: Suggest increased hazard at 25(OH)D levels below 15–20 ng/mL (see figure 2, page 508).

UI | Author Year | Comments for Results
18180395 | Wang 2008 | There are also analyses based on prespecified subgroups analyses by HTN status.

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
18180395 | Wang 2008 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | nd | a) Method reported? (y/n) | NA | a) One of the prespecified methods *** was used? (y/n) | Y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
18180395 | Wang 2008 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | NA | Time from sample collection to sample analysis reported? (y/n) | Y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
18180395 | Wang 2008 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | NA | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | A (though C for 3 category results)
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Rigorous, appropriate adjustments (except for 3 category results, which were not fully adjusted, particularly including season), well analyzed and reported.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Weng 2008

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
18988909 | Weng 2008 | Cohort study | > 40 yrs old (n=3282) Total energy intake range between 500 to 5500 kcal/d for men and 500 to 4000 kcal/d for women | Hx of cancer, stroke which may have changed their dietary habits (n=84), and people who had missing values for FFQ (n=613), for other variables (n=797), or was lost to follow-up (n=11). Also excluded those with extreme dietary data (n=5) | 1989–2002 | CVD- FACTS | National Health Research Institutes in Taiwan | MB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
18988909 | Weng 2008 | Cohort study | Taiwan | 3282 | 1772 | Stroke group = 62.6(8.1) Nonevent group=56.1(9.8) | nd | 44% | nd | Mean BMI stroke group=25.3(3.4) Mean BMI nonevent group=24.4(3.3) | 10.5% diabetics, 4.2% self-report heart disease, 17% use antihypertensive medication | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed information as possible on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data ...etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
18988909 | Weng 2008 | Dietary calcium intake | FFQ | nd | N (but authors state that the FFQ was validated previously by comparing to 15- days food records) | no | | | nd | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
18988909 | Weng 2008 | nd | stroke | Self-reported and cross-checked by medical records or death certificates

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
18988909 | Weng 2008 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
18988909 | Weng 2008 | Demographics (e.g., age, gender, race, education)? | Yes | Matched on gender, adjusted for age
18988909 | Weng 2008 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No
18988909 | Weng 2008 | Medical conditions | Yes | Adjusted for DM, htn, heart disease, hypertriglceridemia
18988909 | Weng 2008 | Medication | Yes | Adjusted for use of htn meds
18988909 | Weng 2008 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
18988909 | Weng 2008 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | Matched on smoking hx, EtOH habits, physical activity
18988909 | Weng 2008 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non- cases/Total N ** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups *** | P for trend ****
18988909 | Weng 2008 | stroke | Quartile 3 + Quartile 4 | | >591.50 mg | | | 127 | adjusted | HR | reference
| | | Quartile 2 | | 451.24–591.50 mg | | | 127 | adjusted | HR | 1.49 | 0.99–2.24
| | | Quartile 1 | | <451.24 | | | 127 | adjusted | HR | 1.52 | 0.98–2.35 | | 0.031

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
18988909 | Weng 2008 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | Nd | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
18988909 | Weng 2008 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | Nd | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
18988909 | Weng 2008 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of fina l adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | N | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | No data on exposure assessor blinded to outcome or outcome assessor blinded to exposure. Food composition database not reported.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Whelton, 1997

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
9022561 | Whelton, 1997 | RCT | Healthy, 30–54 yo DBP 80–89 mm Hg | Treatment with antihypertensive | 1987–88 | TOHP | nd | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
9022561 | Whelton, 1997 | RCT | 10 sites | 471 | 445 | 43~+/− 6.6 | 30–54 | 68% | 86% white | ~83 Kg BMI ~27 | Healthy Borderline DBP | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
9022561 | Whelton, 1997 | Dietary calcium intake | none | NA | NA | | | | | none

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
9022561 | Whelton, 1997 | Ca supplement | Ca carbonate | 1 g | 18 mo | 500 mg 2x/day
| | Placebo
Co-intervention(s) * : | | | None
Compliance/Adherence: | | | nd for Ca vs Placebo arms

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
9022561 | Whelton, 1997 | 1° | Change in SBP/DBP

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
9022561 | Whelton, 1997 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
9022561 | Whelton, 1997 | Demographics (e.g., age, gender, race, education)? | No
9022561 | Whelton, 1997 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No
9022561 | Whelton, 1997 | Medical conditions
9022561 | Whelton, 1997 | Medication
9022561 | Whelton, 1997 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
9022561 | Whelton, 1997 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | No
9022561 | Whelton, 1997 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline SD * | Final or Delta ** | Final or Delta CI/SE/SD * | Net difference | Net difference CI/SE/SD * | P between
9022561 | Whelton, 1997 | SBP | mm Hg | Ca supplement | 18 mo | 221 | 126.0 | 7.7 | nd | nd | ~−0.5 (figure) | ~0.75 | NS
9022561 | Whelton, 1997 | SBP | mm Hg | Placebo | | 224 | 125.4 | 8.8 | nd | nd
9022561 | Whelton, 1997 | DBP | mm Hg | Ca supplement | 18 mo | 221 | 84.1 | 2.9 | nd | nd | ~+0.3 (figure) | ~0.5 | NS
9022561 | Whelton, 1997 | DBP | mm Hg | Placebo | | 224 | 83.9 | 2.8 | nd | nd

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
9022561 | Whelton, 1997 | RCT | nd | nd | NA | Y | nd | nd | probably | N | N | C
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | No data on background diet. Ca vs Placebo analysis very poorly reported. Primary outcome of HTN incidence not reported. Clear results data not presented. Results not in text of results section.

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Wu, 1987

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
3620314 | Wu, 1987 | Cohort study | Residents who moved into the Large retirement community between June, 1981 and June 1982 were mailed a questionnaire on June 1982. A total of 11,888 (625) of the 19,752 residents returned the questionnaire. | Pre-existing CRC were excluded from the analysis | 1982 | nd | nd | MC

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
3620314 | Wu, 1987 | Cohort study | About 50 miles south of Los Angeles, California [21° N] | 11,888 | 11,644 | nd | nd (to adjust for age, the cohort were divided into 4 age strata: <=64, 65–74, 75–84, >=85) | ~33% | 100% Caucasian (upper-middle socio- economic class) | nd | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed information as possible on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
3620314 | Wu, 1987 | Dietary calcium intake | FFQ–56 foods and coffee | USDA | N | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
3620314 | Wu, 1987 | nd | Colorectal cancer | Pathological diagnosis of cancer from local hospitals was available among 85% study participants. In addition, all participants are sent a follow-up questionnaire on a biennial basis. All residents were followed until the diagnosis of CRC, death or March 31, 1985 whichever occurred first.

UI | Author Year | Comments
3620314 | Wu, 1987 | No main result for calcium and CRC. Only subgroup analysis results by gender.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
3620314 | Wu, 1987 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
3620314 | Wu, 1987 | Demographics (e.g., age, gender, race, education)? | Yes *
3620314 | Wu, 1987 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no *
3620314 | Wu, 1987 | Medical conditions
3620314 | Wu, 1987 | Medication
3620314 | Wu, 1987 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
3620314 | Wu, 1987 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no *
3620314 | Wu, 1987 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

Subgroup Analyses

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | Total N * * | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI * * | P between groups * * * | P for trend * * * *
3620314 | Wu, 1987 | CRC - male | Calcium intake Tertile 1 (low) | nd | nd | nd | nd * | Person- yrs= 13875 | adjusted | RR | 1 | | nd | nd
| | | Tertile 2 | nd | nd | nd | nd * | Person- yrs= 13840 | adjusted | RR | 1.19 | 0.6, 2.2
| | | Tertile 3 (high) | nd | nd | nd | nd * | Person- yrs= 13611 | adjusted | RR | 0.86 | 0.4, 1.7
3620314 | Wu, 1987 | CRC - female | Calcium intake Tertile 1 (low) | nd | nd | nd | nd * | 4.5 yr Person- yrs= 13875 | adjusted | RR | 1 | | nd | nd
| | | Tertile 2 | nd | nd | nd | nd * | Person- yrs= 13840 | adjusted | RR | 0.9 | 0.5, 1.6
| | | Tertile 3 (high) | nd | nd | nd | nd * | Person- yrs= 13611 | adjusted | RR | 0.89 | 0.5, 1.6

* Total number of subjects (both male and female) per tertile: tertile 1=3865, tertile 2=3873; tertile 3=3828

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
3620314 | Wu, 1987 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | Y | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | nd | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | N | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | N | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
3620314 | Wu, 1987 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | nd | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | N | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | N | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | nd
3620314 | Wu, 1987 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | N | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Poor reporting of baseline characteristics and exposures’ data. No adjustment for confounding other than age and sex. Confirmation by histology not performed for all cases; number of cases, non-cases per gender not provided

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Wu 2002

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
11904316 | Wu 2002 | Cohort study 1: HPFS Cohort study 2: NHS | HPFS: male dentists, podiatrists, pharmacists, optometrists, osteopaths, and veterinarians who were 40–75 years old and completed a mailed questionnaire requesting information on various exposures and medical diagnosis in 1986; and also completed a 131-item semi-quantitative FFQ at the same year (1986) (follow up FFQ included were mailed during the years: 1990, 1994) NHS: registered US nurses who were 30–55 years old and completed a mailed questionnaire requesting information on various exposures and medical diagnosis in 1976; and completed a 61-item semi- quantitative FFQ in 1980 (follow up FFQ included 121–134 items during the years: 1984, 1986, 1990, 1994) | HPFS: men who failed to fill in the FFQ at baseline or left a large number of items blank (>70); men with unreasonably high (>4200 kcal/day or low (<800 kcal/day) total energy intake; men with history of previous cancer (except for nonmelanoma skin cancer), and ulcerative colitis NHS: women who failed to fill in the FFQ at baseline or left a large number of items blank (>10); women with unreasonably high (>3500 kcal/day or low (<600 kcal/day) total energy intake; women with history of previous cancer (except for nonmelanoma skin cancer), and ulcerative colitis | HPFS: 1986 NHS: 1980 | HPFS: Health Professionals Follow-up Study NHS: Nurses’ Health Study | HPFS: NCI NHS: NCI | AT

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
11904316 | Wu 2002 | Cohort study 1 (HPFS) Cohort study 2 (NHS) | HPFS: nd NHS: US | HPFS: 47344 NHS: 87998 | HPFS: 47344 NHS: 87998 | HPFS: 54.4 (nd) NHS: 46.6 (nd) | HPFS: nd NHS: nd | HPFS: 100 NHS: 0 | HPFS: nd NHS: nd | HPFS: Average BMI (kg/m ^ 2 ^ ): 25.5 NHS: Average BMI (kg/m ^ 2 ^ ): 24.4 | HPFS: %current smokers: 9.6; %aspirin users: 29.3; %family history CRC: 10; %history of polyps: 3.5; %previous endoscopy: 25.8; %current multivitamin supplementation: 41.6 NHS: %current smokers: 28.9; %aspirin users: 32.8; %family history CRC: 8.4; %history of polyps: 0.8; %previous endoscopy: 9.8; %current multivitamin supplementation: 34.1; %menopausal women: 33 | HPFS: Average total energy intake (kcal/day): 1985; average vitamin D intake (IU/day): 363; average calcium intake (mg/day): 897 NHS: Average total energy intake (kcal/day): 1566; average vitamin D intake (IU/day): 292; average calcium intake (mg/day): 733

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
11904316 | Wu 2002 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | NA | NA | NA | NA | NA
11904316 | Wu 2002 | Dietary calcium intake | HPFS: FFQ NHS: FFQ | HPFS: USDA and others (REF 33–36) NHS: USDA and others (REF 33–36) | y (REF 33–36) HPFS: Pearson correlation coefficient (energy adjusted) between calcium intake computed from the FFQ and average calcium intake of two 1-week diet records for 127 men: 0.53 (with supplements and without supplements) NHS: Pearson correlation coefficient (energy adjusted) between calcium intake computed from the FFQ and average calcium intake of two 1-week diet records for 191 women: 0.63 (with supplements); and 0.70 (without supplements) | | | | | NA

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
11904316 | Wu 2002 | primary | Primary adenocarcinoma | Reported as diagnosis of colon or rectal cancer by the patients and confirmed by reviewing medical records of pathology reports. Data extracted from pathology reports included: histology, anatomic location, and sage of cancer
| | primary | Proximal (right sided) colon cancer | Colon cancer located in cecum, ascending colon, or transverse colon
| | primary | Distal (left sided) colon cancer | Colon cancer located in descending colon, or sigmoid colon

UI | Author Year | Comments
11904316 | Wu 2002 | 86 cases with colorectal cancer in HPFS and 97 cases with colorectal cancer in NHS were included in the analyses with missing information on anatomic site. These additional cases were confirmed by medical records, by autopsy, or death reports, or by reconfirming the self-reported diagnosis from the patients. Exclusion of these cases yielded similar results. Death was confirmed by the National Death Index or reports from family members

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
11904316 | Wu 2002 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes (red meat consumption)
11904316 | Wu 2002 | Demographics (e.g., age, gender, race, education)? | Yes (Age)
11904316 | Wu 2002 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes (BMI)
11904316 | Wu 2002 | Medical conditions | Yes (family history CRC; for NHS only: menopausal status)
11904316 | Wu 2002 | Medication | Yes (aspirin use; for NHS only: post-menopausal hormone use)
11904316 | Wu 2002 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | No
11904316 | Wu 2002 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes (physical activity; pack-years of smoking before age 30; alcohol consumption)
11904316 | Wu 2002 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

HPFS: adjusted for age, BMI, family history CRC, aspirin use, red meat consumption, physical activity; pack-years of smoking before age 30, alcohol consumption (5 out of 313 confirmed cancer case subjects were excluded for cancer from subsite analyses because of insufficient information on cancer location)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | No. of Non- cases/Total N** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups*** | P for trend****
11904316 | Wu 2002 | Primary adenocarcinoma (CRC) | Cumulative average calcium intake (mg) | | ≤ 500 | 47 | nd | nd | adjusted | RR | 1.00 | | nd | 0.17
| | | Cumulative average calcium intake (mg) | | 501– 600 | 48 | nd | nd | adjusted | RR | 0.69 | 0.46– 1.04 | nd | 0.17
| | | Cumulative average calcium intake (mg) | | 601– 700 | 58 | nd | nd | adjusted | RR | 0.69 | 0.47– 1.01 | nd | 0.17
| | | Cumulative average calcium intake (mg) | | 701– 800 | 51 | nd | nd | adjusted | RR | 0.60 | 0.40– 0.90 | nd | 0.17
| | | Cumulative average calcium intake (mg) | | 801– 100 | 81 | nd | nd | adjusted | RR | 0.67 | 0.47– 0.97 | nd | 0.17
| | | Cumulative average calcium intake (mg) | | 1001– 1250 | 84 | nd | nd | adjusted | RR | 0.62 | 0.42– 0.92 | nd | 0.17
| | | Cumulative average calcium intake (mg) | | >1250 | 60 | nd | nd | adjusted | RR | 0.64 | 0.43– 0.95 | nd | 0.17
| | Proximal (right sided) colon cancer | Cumulative average calcium intake (mg) | | ≤ 500 | 12 | nd | nd | adjusted | RR | 1.00 | | nd | 0.91
| | | Cumulative average calcium intake (mg) | | 501– 600 | 15 | nd | nd | adjusted | RR | 0.84 | 0.39– 1.81 | nd | 0.91
| | | Cumulative average calcium intake (mg) | | 601– 700 | 19 | nd | nd | adjusted | RR | 0.87 | 0.42– 1.79 | nd | 0.91
| | | Cumulative average calcium intake (mg) | | 701– 800 | 22 | nd | nd | adjusted | RR | 0.98 | 0.48– 1.99 | nd | 0.91
| | | Cumulative average calcium intake (mg) | | 801– 100 | 34 | nd | nd | adjusted | RR | 1.06 | 0.54– 2.07 | nd | 0.91
| | | Cumulative average calcium intake (mg) | | 1001– 1250 | 24 | nd | nd | adjusted | RR | 1.01 | 0.50– 2.05 | nd | 0.91
| | | Cumulative average calcium intake (mg) | | >1250 | 24 | nd | nd | adjusted | RR | 0.92 | 0.45– 1.87 | nd | 0.91
| | Distal (left sided) colon cancer | Cumulative average calcium intake (mg) | | ≤ 500 | 22 | nd | nd | adjusted | RR | 1.00 | | nd | 0.12
| | | Cumulative average calcium intake (mg) | | 501– 600 | 25 | nd | nd | adjusted | RR | 0.77 | 0.43– 1.37 | nd | 0.12
| | | Cumulative average calcium intake (mg) | | 601– 700 | 25 | nd | nd | adjusted | RR | 0.64 | 0.36– 1.14 | nd | 0.12
| | | Cumulative average calcium intake (mg) | | 701–800 | 16 | nd | nd | adjusted | RR | 0.41 | 0.21–0.78 | nd | 0.12
| | | Cumulative average calcium intake (mg) | | 801– 100 | 28 | nd | nd | adjusted | RR | 0.51 | 0.29– 0.91 | nd | 0.12
| | | Cumulative average calcium intake (mg) | | 1001– 1250 | 18 | nd | nd | adjusted | RR | 0.46 | 0.24– 0.86 | nd | 0.12
| | | Cumulative average calcium intake (mg) | | >1250 | 24 | nd | nd | adjusted | RR | 0.58 | 0.32– 1.05 | nd | 0.12

NHS: adjusted for age, BMI, family history CRC, aspirin use, red meat consumption, physical activity; pack-years of smoking before age 30, alcohol consumption, post-menopausal hormone use, menopausal status

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | No. of Non- cases/Total N** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups*** | P for trend****
11904316 | Wu 2002 | Primary adenocarcinoma (CRC) | Cumulative average calcium intake (mg) | | ≤ 500 | 70 | nd | nd | adjusted | RR | 1.00 | | nd | 0.35
| | | Cumulative average calcium intake (mg) | | 501– 600 | 79 | nd | nd | adjusted | RR | 1.19 | 0.86– 1.64 | nd | 0.35
| | | Cumulative average calcium intake (mg) | | 601– 700 | 83 | nd | nd | adjusted | RR | 1.07 | 0.77– 1.47 | nd | 0.35
| | | Cumulative average calcium intake (mg) | | 701– 800 | 90 | nd | nd | adjusted | RR | 1.18 | 0.86– 1.63 | nd | 0.35
| | | Cumulative average calcium intake (mg) | | 801– 100 | 130 | nd | nd | adjusted | RR | 1.04 | 0.77– 1.40 | nd | 0.35
| | | Cumulative average calcium intake (mg) | | 1001– 1250 | 106 | nd | nd | adjusted | RR | 1.05 | 0.77– 1.44 | nd | 0.35
| | | Cumulative average calcium intake (mg) | | >1250 | 68 | nd | nd | adjusted | RR | 0.94 | 0.66– 1.33 | nd | 0.35
| | Proximal (right sided) colon cancer | Cumulative average calcium intake (mg) | | ≤ 500 | 27 | nd | nd | adjusted | RR | 1.00 | | nd | 0.32
| | | Cumulative average calcium intake (mg) | | 501– 600 | 25 | nd | nd | adjusted | RR | 0.92 | 0.53– 1.61 | nd | 0.32
| | | Cumulative average calcium intake (mg) | | 601– 700 | 37 | nd | nd | adjusted | RR | 1.18 | 0.72– 1.96 | nd | 0.32
| | | Cumulative average calcium intake (mg) | | 701– 800 | 46 | nd | nd | adjusted | RR | 1.55 | 0.96– 2.52 | nd | 0.32
| | | Cumulative average calcium intake (mg) | | 801– 100 | 56 | nd | nd | adjusted | RR | 1.13 | 0.70– 1.81 | nd | 0.32
| | | Cumulative average calcium intake (mg) | | 1001– 1250 | 50 | nd | nd | adjusted | RR | 1.28 | 0.79– 2.08 | nd | 0.32
| | | Cumulative average calcium intake (mg) | | >1250 | 35 | nd | nd | adjusted | RR | 0.28 | 0.75– 2.16 | nd | 0.32
| | Distal (left sided) colon cancer | Cumulative average calcium intake (mg) | | ≤ 500 | 33 | nd | nd | adjusted | RR | 1.00 | | nd
| | | Cumulative average calcium intake (mg) | | 501– 600 | 37 | nd | nd | adjusted | RR | 1.24 | 0.77– 2.00 | nd | 0.06
| | | Cumulative average calcium intake (mg) | | 601– 700 | 40 | nd | nd | adjusted | RR | 1.16 | 0.72– 1.85 | nd | 0.06
| | | Cumulative average calcium intake (mg) | | 701– 800 | 33 | nd | nd | adjusted | RR | 0.98 | 0.60– 1.61 | nd | 0.06
| | | Cumulative average calcium intake (mg) | | 801– 100 | 46 | nd | nd | adjusted | RR | 0.78 | 0.49– 1.25 | nd | 0.06
| | | Cumulative average calcium intake (mg) | | 1001– 1250 | 40 | nd | nd | adjusted | RR | 0.91 | 0.56– 1.48 | nd | 0.06
| | | Cumulative average calcium intake (mg) | | >1250 | 24 | nd | nd | adjusted | RR | 0.73 | 0.41– 1.27 | nd | 0.06

NHS: adjusted for age, BMI, family history CRC, aspirin use, red meat consumption, physical activity; pack-years of smoking before age 30, alcohol consumption, post-menopausal hormone use, menopausal status

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | Total N ** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
11904316 | Wu 2002 | Primary adenocarcinoma (CRC) | Total calcium intake at baseline (mg/day) | | Lowest category | nd | 20,599 | nd | adjusted | RR | 1.00 | | nd
11904316 | Wu 2002 | Primary adenocarcinoma (CRC) | Total calcium intake at baseline (mg/day) | | Highest category | nd | 5636 | nd | adjusted | RR | 0.83 | 0.64– 1.09 | nd

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

HPFS and NHS: pooled analysis adjusted for age, BMI, family history CRC, aspirin use, red meat consumption, physical activity; pack-years of smoking before age 30, alcohol consumption, post-menopausal hormone use, menopausal status

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | No. of Non- cases/Total N** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups*** | P for trend****
11904316 | Wu 2002 | Proximal (right sided) colon cancer | Cumulative average calcium intake (mg) | | ≤ 500 | 70 | nd | nd | adjusted | RR | 1.00 | | nd | 0.41
| | | Cumulative average calcium intake (mg) | | 501– 600 | 79 | nd | nd | adjusted | RR | 0.90 | 0.57– 1.04 | nd | 0.41
| | | Cumulative average calcium intake (mg) | | 601– 700 | 83 | nd | nd | adjusted | RR | 1.07 | 0.71– 1.62 | nd | 0.41
| | | Cumulative average calcium intake (mg) | | 701– 800 | 90 | nd | nd | adjusted | RR | 1.33 | 0.87– 2.04 | nd | 0.41
| | | Cumulative average calcium intake (mg) | | 801– 100 | 130 | nd | nd | adjusted | RR | 1.10 | 0.75– 1.63 | nd | 0.41
| | | Cumulative average calcium intake (mg) | | 1001– 1250 | 106 | nd | nd | adjusted | RR | 1.19 | 0.80– 1.77 | nd | 0.41
| | | Cumulative average calcium intake (mg) | | >1250 | 68 | nd | nd | adjusted | RR | 0.14 | 0.72– 1.81 | nd | 0.41
| | Distal (left sided) colon cancer | Cumulative average calcium intake (mg) | | ≤ 500 | 70 | nd | nd | adjusted | RR | 1.00 | | nd | 0.01
| | | Cumulative average calcium intake (mg) | | 501– 600 | 79 | nd | nd | adjusted | RR | 1.01 | 0.64– 1.59 | nd | 0.01
| | | Cumulative average calcium intake (mg) | | 601– 700 | 83 | nd | nd | adjusted | RR | 0.88 | 0.50– 1.57 | nd | 0.01
| | | Cumulative average calcium intake (mg) | | 701– 800 | 90 | nd | nd | adjusted | RR | 0.65 | 0.28– 1.53 | nd | 0.01
| | | Cumulative average calcium intake (mg) | | 801– 100 | 130 | nd | nd | adjusted | RR | 0.65 | 0.44– 0.98 | nd | 0.01
| | | Cumulative average calcium intake (mg) | | 1001– 1250 | 106 | nd | nd | adjusted | RR | 0.67 | 0.34– 1.30 | nd | 0.01
| | | Cumulative average calcium intake (mg) | | >1250 | 68 | nd | nd | adjusted | RR | 0.65 | 0.43– 0.98 | nd | 0.01

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
11904316 | Wu 2002 | HPFS: follow up years, 1986–1996; multivariate adjustment did not substantially alter the age specific estimates; results were similar when baseline total calcium intake was used without updating dietary information. NHS: follow up years, 1980–1996; multivariate adjustment did not substantially alter the age specific estimates; the inverse association between CRC and baseline total calcium intake (without updating dietary information) was stronger

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

HPFS

UI | Author Year | Population | | Exposure (All) | | Dietary assessment* | | Biomarkers* | | Comparator | | Statistical Analysis | | Outcome | | Design
11904316 | Wu 2002 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | N | a) Method reported? (y/n) | Y | a) One of the prespecified methods*** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | | a) Adjusted or matched for ANY confounders (other than age and sex)?** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
11904316 | Wu 2002 | b) Sampling of population random or consecutive? (y/n) | N | b) Outcome assessor blinded to exposure measurement? (y/n) | N | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | | a) Adjusted or matched for ANY confounders (other than age and sex)?** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
11904316 | Wu 2002 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Y | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Assessor blinding not reported; post-hoc analyses; power calculation not reported; results are not reported completely; data on several analyses are not shown

NHS

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
11904316 | Wu 2002 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | N | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
11904316 | Wu 2002 | b) Sampling of population random or consecutive? (y/n) | N | b) Outcome assessor blinded to exposure measurement? (y/n) | N | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
11904316 | Wu 2002 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Y | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Assessor blinding not reported; post-hoc analyses; power calculation not reported; results are not reported completely; data on several analyses are not shown

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Wu 2007

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17623801 | Wu 2007 | Case- cohort study | - Male US health professionals (N=51,129); - subjects provided a blood sample in 1993 –1995 (N=18,225); - Cases: colorectal cancer diagnosed between 1993–01/2002; - Controls: 1:2 matching by age (<2 y), year of enrollment, month of blood donation (<1 mo) | nd | 1986 | Health Professionals Follow-up Study (HPFS) cohort | National Cancer Institute, National Institutes of Health (DiaSorin Corp (Maker of Vit D assay kit)) | JHL/TTe

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
17623801 | Wu 2007 | Case- cohort study | US, various | Original cohort (N=51,129), subjects provided a blood sample (N=18,225), cases (N=179) and controls (n=356) | 535 | 66.2 | nd | 100 | nd | BMI 25.7 | Aspirin use in 1994: 40% Current smoking: 5% Previous colonoscopy: 65% | Vit D: 455.7 IU/d Ca: 939 mg/d

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data ...etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
17623801 | Wu 2007 | 25(OH)D | | | | RIA | Intrapair coefficient of variation (CV)=10.1% (n=15 triplets [1 case and 2 matching controls]) | ~7 to 14 y (based on blood collection, last follow-up, submission) | Winter: 28% Spring/Fall: 21% Summer: 52% | 455.7 IU/d
17623801 | Wu 2007 | Dietary calcium intake | FFQ | nd | nd | | | | | 939 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17623801 | Wu 2007 | nd | Colorectal cancer | The vast majority of colorectal cancers (>90%) confirmed through medical records; the remaining cases confirmed by corroborating information on cancer diagnosis from participants.
17623801 | Wu 2007 | nd | Colon cancer | The vast majority of colorectal cancers (>90%) confirmed through medical records; the remaining cases confirmed by corroborating information on cancer diagnosis from participants.
17623801 | Wu 2007 | nd | Proximal colon cancer | The vast majority of colorectal cancers (>90%) confirmed through medical records; the remaining cases confirmed by corroborating information on cancer diagnosis from participants.
17623801 | Wu 2007 | nd | Distal colon cancer | The vast majority of colorectal cancers (>90%) confirmed through medical records; the remaining cases confirmed by corroborating information on cancer diagnosis from participants.
17623801 | Wu 2007 | nd | Rectal cancer | The vast majority of colorectal cancers (>90%) confirmed through medical records; the remaining cases confirmed by corroborating information on cancer diagnosis from participants.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17623801 | Wu 2007 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Intakes of folate, calcium, retinol, meat intake
17623801 | Wu 2007 | Demographics (e.g., age, gender, race, education)? | Yes - age
17623801 | Wu 2007 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes - BMI
17623801 | Wu 2007 | Medical conditions | Family history of colorectal cancer
17623801 | Wu 2007 | Medication | Aspirin use
17623801 | Wu 2007 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | physical activity
17623801 | Wu 2007 | Smoking and other life styles variables | Yes - smoking, alcohol intake
17623801 | Wu 2007 | Other | Fasting status, month of blood donation

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose ***** | Mean Ca level/dose | No. of Cases (Event) * | No. of Non- cases ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
17623801 | Wu 2007 | Colorectal cancer | 25(OH)D–quintile 1 | 18.4 | | 45 | 71 | Adjusted | OR | 1.0 (ref) | | | 0.24
| | | 25(OH)D–quintile 2 | 25.0 | | 44 | 71 | Adjusted | | 0.97 | 0.55–1.70
| | | 25(OH)D–quintile 3 | 29.1 | | 30 | 68 | Adjusted | | 0.66 | 0.35–1.24
| | | 25(OH)D–quintile 4 | 33.3 | | 23 | 74 | Adjusted | | 0.51 | 0.27–0.97
| | | 25(OH)D–quintile 5 | 39.4 | | 37 | 72 | Adjusted | | 0.83 | 0.45–1.52
17623801 | Wu 2007 | Colon cancer | 25(OH)D–quartile 1 | 19.3 | | 49 | 66 | Adjusted | OR | 1.0 (ref) | | | 0.005
| | | 25(OH)D– quartile 2 | 26.7 | | 44 | 68 | Adjusted | | 0.74 | 0.42– 1.33
| | | 25(OH)D– quartile 3 | 32.0 | | 17 | 68 | Adjusted | | 0.29 | 0.14– 0.59
| | | 25(OH)D– quartile 4 | 38.8 | | 29 | 74 | Adjusted | | 0.46 | 0.24– 0.89
17623801 | Wu 2007 | Proximal colon cancer | 25(OH)D– quartile 1 | 19.3 | | 20 | 30 | Adjusted | OR | 1.0 (ref) | | | 0.36
| | | 25(OH)D– quartile 2 | 26.7 | | 21 | 36 | Adjusted | | 0.84 | 0.29– 2.41
| | | 25(OH)D– quartile 3 | 32.0 | | 10 | 35 | Adjusted | | 0.35 | 0.11– 1.09
| | | 25(OH)D– quartile 4 | 38.8 | | 18 | 35 | Adjusted | | 0.69 | 0.23– 2.08
17623801 | Wu 2007 | Distal colon cancer | 25(OH)D– quartile 1 | 19.3 | | 19 | 27 | Adjusted | OR | 1.0 (ref) | | | 0.29
| | | 25(OH)D– quartile 2 | 26.7 | | 16 | 22 | Adjusted | | 0.93 | 0.34– 2.55
| | | 25(OH)D– quartile 3 | 32.0 | | 4 | 21 | Adjusted | | 0.31 | 0.07– 1.36
| | | 25(OH)D– quartile 4 | 38.8 | | 8 | 24 | Adjusted | | 0.71 | 0.21– 2.39
17623801 | Wu 2007 | Rectal cancer | 25(OH)D–tertile 1 | 21.2 | | 11 | 30 | Adjusted | OR | 1.0 (ref) | | | 0.08
| | | 25(OH)D–tertile 2 | 29.3 | | 15 | 28 | Adjusted | | 1.74 | 0.61– 5.00
| | | 25(OH)D–tertile 3 | 37.4 | | 14 | 22 | Adjusted | | 3.32 | 0.87– 12.69
17623801 | Wu 2007 | Colorectal cancer (only >2y since blood donation) | 25(OH)D–quintile 1 | 18.4 | | 36 | 58 | Adjusted | OR | 1.0 (ref) | | | 0.31
| | | 25(OH)D–quintile 2 | 25.0 | | 38 | 55 | Adjusted | | 1.29 | 0.66– 2.51
| | | 25(OH)D–quintile 3 | 29.1 | | 22 | 56 | Adjusted | | 0.63 | 0.31– 1.28
| | | 25(OH)D–quintile 4 | 33.3 | | 20 | 60 | Adjusted | | 0.63 | 0.30– 1.29
| | | 25(OH)D–quintile 5 | 39.4 | | 29 | 59 | Adjusted | | 0.84 | 0.41– 1.72
17623801 | Wu 2007 | Colon cancer(only >2y since blood donation) | 25(OH)D–quartile 1 | 19.3 | | 40 | 55 | Adjusted | OR | 1.0 (ref) | | | 0.008
| | | 25(OH)D– quartile 2 | 26.7 | | 37 | | 52 | Adjusted | | 0.91 | 0.46–1.78
| | | 25(OH)D–quartile 3 | 32.0 | | 16 | | 59 | Adjusted | | 0.32 | 0.15–0.69
| | | 25(OH)D– quartile 4 | 38.8 | | 20 | | 58 | Adjusted | | 0.43 | 0.20–0.94

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

***** medians were calculated among control subject only.

MEAN DATA

THIS SHOULD ONLY APPLY TO CASE-COHORT STUDIES THAT COMPARE BASELINE VIT D/CA LEVELS BETWEEN CASES (WITH DISEASE) AND CONTROLS (WITHOUT DISEASE)

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Mean 25(OH)D Level | Vit D level SD * | Mean Ca intake or Ca balance | Ca SD * | P between groups
17623801 | Wu 2007 | Cases: | 8y | Crude | 179 | 28.7 | 9.2 | 917 | 419 | 0.07 *
17623801 | Wu 2007 | Control: | 8y | Crude | 356 | 29.4 | 8.6 | 950 | 422

Duplicate one table per outcome

* p value for plasma 25(OH)D concentrations

Subgroup Analyses

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose***** | Mean Ca level/dose | No. of Cases (Event)* | No. of Non- cases** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups*** | P for trend****
17623801 | Wu 2007 | Age<65y Colorectal cancer | 25(OH)D–quartile 1 | 19.3 | | 25 | 34 | Adjusted | OR | 1.0 (ref) | | | 0.13
| | | 25(OH)D–quartile 2 | 26.7 | | 15 | 28 | Adjusted | | 1.03 | 0.36– 2.91
| | | 25(OH)D–quartile 3 | 32.0 | | 9 | 30 | Adjusted | | 0.38 | 0.12– 1.26
| | | 25(OH)D–quartile 4 | 38.8 | | 14 | 36 | Adjusted | | 0.45 | 0.15– 1.40
17623801 | Wu 2007 | Age≥65y Colorectal cancer | 25(OH)D–quartile | 19.3 | | 34 | 55 | Adjusted | OR | 1.0 (ref) | | | 0.34
| | | 25(OH)D–quartile 2 | 26.7 | | 36 | 61 | Adjusted | | 0.97 | 0.50– 1.87
| | | 25(OH)D–quartile 3 | 32.0 | | 19 | 58 | Adjusted | | 0.56 | 0.27– 1.15
| | | 25(OH)D–quartile 4 | 38.8 | | 27 | 54 | Adjusted | | 0.83 | 0.39– 1.75

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
17623801 | Wu 2007 | a) Eligibility criteria clear? (y/n) | nd | a) Exposure assessor blinded to outcome info? (y/n) | Y | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | Y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
17623801 | Wu 2007 | b) Sampling of population random or consecutive? (y/n) | nd | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | N | applicable for categorical analyses only | | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | NA | b) Analysis was planned when cohort was formed? (y/n) | N
17623801 | Wu 2007 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | N | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Some poor reporting on inclusion criteria, blinding.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Yamamoto 1995

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
7795837 | Yamamoto 1995 | RCT | -high-normal DBP (80 to 90 mm Hg) and not taking antihypertensive drugs -BMI < 36.15 kg/m ^ 2 ^ -black or white | -preexisting cardiovascular or life-threatening conditions -conditions requiring or contraindicating and of the study interventions -intent to become pregnant during the study period -consuming more than 21 alcohol-containing drinks weekly | nd | Trials of Hypertension Prevention (TOHP) | NHLBI NIH | MB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
7795837 | Yamamoto 1995 | RCT | US, various | 471 | 447 at 3 mo. 438 at 6 mo. | 43±6.5 | Age range: 30–54 | 69% | 86% white 10.5% black | BMI=27.4±3.7 | “healthy” | Ca intake= 970mg/d 24-hr urinary Ca=189 mg

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
7795837 | Yamamoto 1995 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | nd | nd | nd | nd
7795837 | Yamamoto 1995 | Dietary calcium intake | 24-hr diet recall, FFQ | nd | n | | | | | Ca 970mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
7795837 | Yamamoto 1995 | Ca | Calcium carbonate | 1 g Ca | 6 mo. | Pills were taken 2 times a day
7795837 | Yamamoto 1995 | placebo | nd | N/A | 6 mo. | Pills were taken 2 times a day
Co-intervention(s) * :
Compliance/Adherence: | | | Eligibility for randomization required consumption of at least two-thirds of 6 wks of supplement placebo dosing. During the study, pill counts were similar among race-gender subgroups and averaged 95% (with three-fourths taking at least 95% of their supplements).

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
7795837 | Yamamoto 1995 | 1° | Δ in DBP
| | 1° | Δ in SBP
| | nd | BMI

UI | Author Year | Comments
7795837 | Yamamoto 1995 | Eligibility blood pressures (baseline) were calculated from the average of 9 seated readings taken over 3 visits, 10 to 30 days apart. Final pressures were calculated from 9 readings at 6 months. Blood pressure was taken by certified technicians using standardized techniques with a Hawksley random-zero sphygmomanometer. Pressures were taken at the visit’s start after the subject had been seated for 5 minutes. The first and fifth Korotkoff sounds were recorded.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
7795837 | Yamamoto 1995 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
7795837 | Yamamoto 1995 | Demographics (e.g., age, gender, race, education)? | | Ca/placebo groups similar age, race/gender, and education
7795837 | Yamamoto 1995 | Anthropometrics (e.g., BMI, body weight, % body fat)? | | Ca/placebo group similar BMI
7795837 | Yamamoto 1995 | Medical conditions
7795837 | Yamamoto 1995 | Medication
7795837 | Yamamoto 1995 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
7795837 | Yamamoto 1995 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | | Ca/placebo groups similar % current smokers and EtOH intake
7795837 | Yamamoto 1995 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline SD * | Delta ** | Delta SD * | Net difference | Net difference CI/SE/SD * | P between
7795837 | Yamamoto 1995 | BMI | kg/m ^ 2 ^ | Ca | 6 mo. | 217 | 27.4 | 3.7 | +0.07 | 0.95 | −0.05 | | NS
7795837 | Yamamoto 1995 | BMI | kg/m ^ 2 ^ | placebo | 6 mo. | 218 | 27.0 | 3.7 | +0.12 | 1.02

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
7795837 | Yamamoto 1995 | Overall, active treatment and placebo groups showed no significant differences for DBP or SBP after 3 or 6 months of Ca supplementation. Black men taking Ca showed BP increases, but CIs were wide.

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline SD * | Final or Delta ** | Final or Delta CI/SE/SD * | Net difference | Net difference CI/SE/SD * | P between
7795837 | Yamamoto 1995 | DBP in white women | mmHg | Ca | 6 mo | 62 | 83.8 | 2.9 | | | −1.89 | | < 0.05
7795837 | Yamamoto 1995 | DBP in white women | mmHg | placebo | 6 mo | 60 | 83.5 | 2.9
7795837 | Yamamoto 1995 | SBP in white women | mmHg | Ca | 3 mo | 62 | 126.3 | 8.1 | | | −3.68 | | < 0.05
7795837 | Yamamoto 1995 | SBP in white women | mmHg | placebo | 3 mo | 60 | 124.2 | 9.1
7795837 | Yamamoto 1995 | SBP in white women | mmHg | Ca | 6 mo | 62 | 126.3 | 8.1 | | | −2.99 | | = 0.06
7795837 | Yamamoto 1995 | SBP in white women | mmHg | placebo | 6 mo | 60 | 124.2 | 9.1

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

≥2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure Category/Intervention Group | Crude or Adjusted analysis? | Mean Follow-up (months) | No. Analyzed | Baseline | Baseline CI/SE/SD * | Delta ** | Final or Delta CI/SE/SD * | Net difference *** | Net difference CI/SE/SD * | P between groups ***
7795837 | Yamamoto 1995 | SBP in white women | mmHg | 20.3–124.9 mg urinary Ca | Adjusted | 3 mo. | | | | −8 | | | | P < 0.05 (vs. placebo)
| | | | 125.0–169.0 | | 3 mo.
| | | | 169.1–235.9 | | 3 mo.
| | | | 236–606.4 | | 3 mo.
7795837 | Yamamoto 1995 | DBP in white women | | 20.3–124.9 | | 6 mo. | | | | −5 | | | | P < 0.01 (vs. placebo)
| | | | 125.0–169.0 | | 6 mo.
| | | | 169.1–235.9 | | 6 mo.
| | | | 236–606.4 | | 6 mo.

Duplicate one row per exposure category or intervention group. Please write “nd” if there was no data reported. DO NOT LEAVE BLANK.

* Please choose one and delete the others

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline SD * | Delta ** | Delta SD * | Net difference | Net difference CI/SE/SD * | P between
7795837 | Yamamoto 1995 | BMI in white men | kg/m ^ 2 ^ | Ca | 6 mo. | 130 | 27.6 | 3.5 | −0.04 | 0.84 | −0.02 | | NS
7795837 | Yamamoto 1995 | BMI in white men | kg/m ^ 2 ^ | placebo | 6 mo. | 129 | 27.1 | 3.5 | −0.02 | 1.05
| | BMI in black men | | Ca | 6 mo. | 12 | 28.0 | 4.0 | +0.58 | 0.46 | +0.64 | | NS
| | BMI in black men | | placebo | 6 mo. | 11 | 28.4 | 4.9 | −0.06 | 1.30
| | BMI in white women | | Ca | 6 mo. | 59 | 27.5 | 3.9 | +0.19 | 1.18 | −0.14 | | NS
| | BMI in white women | | placebo | 6 mo. | 55 | 26.6 | 3.9 | +0.33 | 0.96
| | BMI in black women | | Ca | 6 mo. | 7 | 25.7 | 4.3 | +0.28 | 1.00 | −0.34 | | NS
| | BMI in black women | | placebo | 6 mo. | 13 | 27.3 | 3.6 | +0.62 | 0.64

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
7795837 | Yamamoto 1995 | RCT- parallel | Y | Y | NA | Y | nd | N | Y | Y | Y | A
Adverse Event(s): ** | | | | | For the Ca group compared to the placebo group, excessive gas and bloating were more frequently reported by white women at 3 months and by whites, in general, at 6 months, and white men reported more loose stools at 6 months.
Explanation for Overall Quality Grade (if not Grade A): | | | | | No major problems

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Zheng 1998

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
9521437 | Zheng 1998 | Cohort study | Women 55–69 years old who completed a mailed questionnaire in January 1986 and were followed for mortality and cancer incidence for 9 years | Baseline history of cancer, including melanoma; 30 or more blanks on the dietary questionnaire; determined to have extreme total energy intake (<600 or≥000 kcal/day); not postmenopausal | 1986 | Iowa Women’s Health Study | US NCI | AT

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
9521437 | Zheng 1998 | Cohort study | Iowa, US (40° 23′ – 40°30′ N) | 34702 | 34702 | nd | 55–59 years old: 107377 person-yr; 60–64 years old: 104081 person-yr; ≥ 65 years old: 81632 person-yr | 0 | nd | nd | Pack-yr of smoking: Never 192,062 person- yr; <30 pack-yr; 54,287 person-yr; ≥30 pack-yr 40,695 person-yr Hormone replacement therapy: Never 179,130 person- yr; <5 years 79,408 3 person- yr; ≥5 years 31,946 person-yr Post- menopausal: 100% | Total energy intake (tertile, kcal/day) <1499.1: 97428 person-yr; 1499.1– 1970.3: 97685 person-yr; ≥1940.4: 97987 person-yr Total fat intake (tertile, g/day) <54.6: 97319 person-yr; 54.6– 75.9: 97506 person-yr; ≥76.0: 98266 person-yr Total fruit and vegetable intake (tertile, servings/week) <33.5: 96744 person-yr; 33.5– 48.5: 98806 person-yr; ≥48.6 97540 person-yr

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
9521437 | Zheng 1998 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | NA | NA | NA | NA | NA
9521437 | Zheng 1998 | Dietary calcium intake | Semiquantitative FFQ (by Willet) | USDA Nutrient Database | y For validity and reliability see Munger et al. Am J Epidemiol, 1992 Pearson’s correlation coefficients of nutrient intake from FFQ with those from five 24-h dietary recalls is 0.67 for calcium | | | | | Ca mg/d < 800.8 (n=56), 800.8–1278.8 (n=52), > 1278.7 (n=36)

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
9521437 | Zheng 1998 | secondary | Rectal cancer | State Health Registry of Iowa, part of the Surveillance, Epidemiology, and End Results Program of the National Cancer Institute; cancer of the rectum (International Classification of Diseases-Oncology, code = 154)

UI | Author Year | Comments
9521437 | Zheng 1998 | Primary outcome: mortality; cancer incidence

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
9521437 | Zheng 1998 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes (total energy intake)
9521437 | Zheng 1998 | Demographics (e.g., age, gender, race, education)? | Yes (age)
9521437 | Zheng 1998 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes (body mass index, fat and protein intake) | in some analyses
9521437 | Zheng 1998 | Medical conditions | No
9521437 | Zheng 1998 | Medication | Yes (use of hormone replacement therapy)
9521437 | Zheng 1998 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | No
9521437 | Zheng 1998 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes (smoking status, pack-years of smoking) | in some analyses also: alcohol consumption, physical activity
9521437 | Zheng 1998 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non- cases/Total N ** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups *** | P for trend ****
9521437 | Zheng 1998 | Rectal cancer | Low total calcium intake tertile (mg/day) | | <800.8 | 56 | nd | 108 | adjusted | RR | 1.00 | | | 0.02
9521437 | Zheng 1998 | Rectal cancer | Intermediate total calcium intake tertile (mg/day) | | 800.8–1278.7 | 52 | nd | 108 | adjusted | RR | 0.90 | 0.61–1.33 | nd | 0.02
9521437 | Zheng 1998 | Rectal cancer | High total calcium intake tertile (mg/day) | | ≥1278.7 | 36 | nd | 108 | adjusted | RR | 0.59 | 0.37–0.94 | nd

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
9521437 | Zheng 1998 | Follow up: 9 years. Subgroup analysis was also conducted based on intake sources of calcium (supplement vs. no supplement group)

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
9521437 | Zheng 1998 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | N | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
| | b) Sampling of population random or consecutive? (y/n) | N | b) Outcome assessor blinded to exposure measurement? (y/n) | N | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | Y
| | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Y | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | Y | Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Study designed for cancer incidence and mortality; not specifically for rectal cancer; power calculation for rectal cancer not stated; number of women without cancer per calcium tertile not reported; blinding for assessors not reported; confirmation of cancer cases by histology not reported

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Zhu 2008a

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
18089701 | Zhu 2008 | RCT- post hoc | Substudy of the larger Calcium Intake Fracture Outcome Study (N=1500). The first 120 sequential patients presenting in September 1998 (end of winter in Western Australia) enrolled in this substudy. Aged 70 yr old, and not receiving bone active agent | nd | 1998 | Substudy of Calcium Intake Fracture Outcome Study | Healthway Health Promotion Foundation of Western Australia, the Australian Menopause Society, and the Australian National Health and Medical Research Council | JHL MC

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
18089701 | Zhu 2008 | RCT | Western Australia | 120 | 120 | 74.8 (2.6) | nd | 0% | nd | nd | nd (some subjects, unclear how many developed cancer or vascular disease during the study) | “living in sunny climate”

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
18089701 | Zhu 2008 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | 25(OH)D - competitive protein biding essay | n | nd | September 1998 (end of winter in Western Australia) | 68.0 (28.7) nmol/liter
18089701 | Zhu 2008 | Dietary calcium intake | Semiquantitative food frequency questionnaire | nd | nd | | | | | 1010 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
18089701 | Zhu 2008 | Ca group + Placebo vitD | Ca (Caltrate; Wyeth Consumer Healthcare, Baulkham Hills, New South Wales, Australia) | Ca 1200 mg | 5y | 600 mg of Ca twice/day
18089701 | Zhu 2008 | Ca group + Placebo vitD | Placebo vitD (nd) | Ca 1200 mg | 5y | 600 mg of Ca twice/day
18089701 | Zhu 2008 | CaD group | Ca (Caltrate; Wyeth Consumer Healthcare, Baulkham Hills, New South Wales, Australia) | Ca 1200 mg VitD2 1000 IU | 5y | 600 mg of Ca twice/day 1000 IU of vitD2 once/day
18089701 | Zhu 2008 | CaD group | VitD2 (Ostelin; Boots Healthcare, North Ryde, New South Wales, Australia) | Ca 1200 mg VitD2 1000 IU | 5y | 600 mg of Ca twice/day 1000 IU of vitD2 once/day
18089701 | Zhu 2008 | Placebo group | Placebo Ca (nd) Placebo vitD (nd) | | 5y
Co-intervention(s) * : | | | None
Compliance/Adherence: | | | Measured by counting tablets returned every 12 months, so significant differences among 3 groups, Ca or placebo in the Ca, CaD, and control groups (80.9, 80.7, and 86.9% respectively), for vitD or placebo (84.2, 86.9, and 89.8% respectively)

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
18089701 | Zhu 2008 | Secondary | 25(OH)D | Measured by competitive protein binding essay after column extraction
18089701 | Zhu 2008 | Primary | BMD | Measured at the hip with an Acclaim 4500A fan beam densitometer (Hologic Corp., Waltham, MA) ay baseline yr 1,3, and 5 using an identical protocol.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
18089701 | Zhu 2008 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Baseline calcium intake and vitamin D status
18089701 | Zhu 2008 | Demographics (e.g., age, gender, race, education)? | Yes * - Age
18089701 | Zhu 2008 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes * - height, body weight
18089701 | Zhu 2008 | Medical conditions
18089701 | Zhu 2008 | Medication
18089701 | Zhu 2008 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
18089701 | Zhu 2008 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes/no *
18089701 | Zhu 2008 | Other | VitD status

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline *** | Baseline SD * | Delta ** | Delta CI/SE/SD * | Net difference | Net difference SD * | P between
18089701 | Zhu 2008 | Hip BMD | mg/cm2 | Ca group + Vit D | 60 | 39/33 | 782.9 | 88.8 | nd | | 2.2 % | 1.1 % | 0.05
18089701 | Zhu 2008 | Hip BMD | mg/cm2 | Placebo | 60 | 41/36 | 827.8 | 125.4 | nd
18089701 | Zhu 2008 | Hip BMD | mg/cm2 | Ca group + Vit D2 | 12 | 39/33 | 782.9 | 88.8 | 0.19 | nd | 1.2 % | 0.6 % | 0.04
18089701 | Zhu 2008 | Hip BMD | mg/cm2 | Placebo | 12 | 41/36 | 827.8 | 125.4 | −1.27
18089701 | Zhu 2008 | Hip BMD | mg/cm2 | Ca group + Placebo vit D | 12 | 40/38 | 833.9 | 92.9 | −0.17 | nd | 1.5 % | 0.5 % | 0.007
18089701 | Zhu 2008 | Hip BMD | mg/cm2 | Placebo | 12 | 41/36 | 827.8 | 125.4 | −1.27

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

*** Baseline data are for all subjects enrolled

≥2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure Category/Intervention Group | Crude or Adjusted analysis? | Mean Follow-up (months) | No. Analyzed | Baseline | Baseline SD * | Final ** | Final SD * | Net difference *** | Net difference CI/SE/SD * | P between groups ***
18089701 | Zhu 2008 | 25(OH)D | nmol/liter | Ca group year 1 | Crude | 12 | 37 | 66.6 | 25.9 | 64.5 | 26.5 | nd | nd | NS
| | | | Ca group year 3 | Crude | 36 | 35 | 66.6 | 25.9 | 74.6 | 23.8 | nd | nd | NS
| | | | Ca group year 5 | Crude | 60 | 34 | 66.6 | 25.9 | 63.7 | 28.7 | nd | nd | NS
18089701 | Zhu 2008 | 25(OH)D | nmol/liter | CaD group year 1 | Crude | 12 | 34 | 70.2 | 25.6 | 97.8 | 31.8 | nd | nd | P < 0.001 vs. Ca or control group
| | | | CaD group year 3 | Crude | 36 | 32 | 70.2 | 25.6 | 118.4 | 44.38 | nd | nd | P < 0.001vs. Ca or control group
| | | | CaD group year 5 | Crude | 60 | 29 | 70.2 | 25.6 | 106.4 | 29.0 | nd | nd | P < 0.001 vs. Ca or control group
18089701 | Zhu 2008 | 25(OH)D | nmol/liter | Control group year 1 | Crude | 12 | 38 | 67.3 | 34.2 | 59.7 | 28.8 | nd | nd | NS
| | | | Control group year 3 | Crude | 36 | 32 | 67.3 | 34.2 | 63.6 | 32.3 | nd | nd | NS
| | | | Control group year 5 | Crude | 60 | 30 | 67.3 | 34.2 | 61.5 | 23.0 | nd | nd | NS

Duplicate one row per exposure category or intervention group. Please write “nd” if there was no data reported. DO NOT LEAVE BLANK.

* Please choose one and delete the others

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
18089701 | Zhu 2008 | Hip BMD | Both Ca and CaD groups had significantly better maintenance of hip BMD than the control group at yr 1 (Ca-control: 1.5±0.5%, p=0.007; CaD- control: 1.2±0.6%, p=0.04). However, only the CaD group had significantly better maintenance of hip BMD, compared with the control group, at yr3 (CaD-control: 2.8±1.1%, p=0.01) and 5 (CaD-control: 2.2±1.1%, P=0.05). In the CaD group, there was no bone loss over the 5 yr of the study. The results were unchanged after adjusted for baseline age, height, and body weight.

UI | Author Year | Comments for Results
18089701 | Zhu 2008 | No year-5 net change BMD data for Ca vs. placebo group but the net difference was not statistically significant. This is a sub study of the larger Calcium Intake Fracture Outcome Study, a 5-yr double-blinded, randomized, controlled calcium supplementation study, in which 1500 community-living ambulant women over the age of 70 yr were randomized to received either 1200mg Calcium per day or identical placebo.

Subgroup Analyses

UI | Author Year | Outcome | Results
18089701 | Zhu 2008 | Hip BMD | Further analysis was carried out by grouping subjects according to the median of the baseline 25OHD values (68nmol/liter). In those patients with 25OHD concentrations below the median, the hip BMD was maintained, compared with controls, whereas in those with higher baseline 25OHD levels, there was no treatment effect.

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
18089701 | Zhu 2008 | RCT-parallel | Y | Y | NA | Y | Y | Y | Y | Y | Y | B
Adverse Event(s): ** | | | | No significant differences among the three groups in the rate of incident cancer or vascular disease. No case of kidney stones was reported.
Explanation for Overall Quality Grade (if not Grade A): | | | | Differential dropout rates between groups. During the study, 2 patients withdrew from the Ca group, 6 from CaD group, and 5 from the control group. The reasons for the two withdrawals in the Ca group were concurrent illnesses or health concerns; in the CaD group, the reasons for withdrawal were personal reasons not related to the study (n=3), concurrent illnesses or health concerns (n=2), and investigator’s decision (n =1). In the control group, the r easons for withdrawal were personal reasons not related to the study (n=1), death (n=2), and investigator’s decision (n=2). Not sure if all subjects had hip BMD measurements (not shown in table or figure, but assumed complete data for BMD in this data extraction form (excluding withdraws). ITT analyses. Not all subjects had 25(OH)D data. Crude analysis for curve 4 data only. Grade C for curve 4 data. No information on food composition database

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Zhu 2008b

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
18410225 | Zhu, 2008 | RCT | Women between 70 and 90 yr of age were recruited from three sources: patients attending the emergency departments of teaching hospitals, patients receiving services from the local community home nursing service (Silver Chain) for management of falls, and the Electoral roll, which lists >98% of women of this age. The inclusion criteria were a plasma 25(OH)D <60 nM and a history of >1 fall in the previous 12 mo. | Current vitamin D consumption, current consumption of bone or mineral active agents apart from calcium, a BMD Z-score at the total hip site of less than −2.0, medical conditions or disorders that influence bone mineral metabolism including lab evidence of renal insufficiency (creatinine >2-fold above the normal value), a fracture in the past 6 mo, and a Mini Mental State Exam score <24 or the presence of significant neurological conditions likely to substantially impair balance or physical activity such as stroke and Parkinson’s disease. | April 2003 and October 2004 | nd | government | MC

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
18410225 | Zhu, 2008 | RCT | Perth, Australia (32 °S) | 302 | 256 | 77 (4.5) | 70 to 90 | 0 | nd | Mean BMI = 29 | nd (based on the inclusion and exclusion criteria, assume subjects were not very healthy but normal physical functioning) | Mean 25(OH)D = 44 nM Only 37% had a calcium intake >1200 mg/d

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed information as possible on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data…etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
18410225 | Zhu, 2008 | 25(OH)D | | | | RIA (DiaSorin, Stillwater, MN, USA) | no | nd | nd | Mean 25(OH)D = 44.3 (12.9) nM; 14% had levels <30 nM.
| | Dietary calcium intake | FFQ | NUTTAB 90 | no | no | | | | Mean calcium intake = 1097 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
18410225 | Zhu, 2008 | Vitamin D2 + Calcium | Ostelin; Boots Healthcare, North Ryde, Australia | 1000 IU vit D2 + 1000 mg/d Ca | 1 yr | Consume with evening meal
| | Calcium + placebo | Calcium citrate (Citracal; Mission Pharmacal, Key Pharmaceutical, Phodes, Ausralia) | 1000 mg/d | 1 yr | Consume with evening meal
Co-intervention(s) * : | | | None
Compliance/Adherence: | | | Tablet counting, 86.7% and 86.8% in the vitamin D and the control groups.

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
18410225 | Zhu, 2008 | primary | BMD | Hip and total body. DXA
| | Secondary | 25(OH)D

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline SD * | Delta ** | Delta SD * | Net difference | Net difference CI/SE/SD * | P between
18410225 | Zhu, 2008 | 25(OH)D | nmol/L | Vit D2 + Ca | 12 | 123 | 44.8 | 12.7 | 34% | nd | 34% | nd | <0.001
18410225 | Zhu, 2008 | 25(OH)D | nmol/L | Ca | 12 | 133 | 43.7 | 12.9 | 0% | nd
18410225 | Zhu, 2008 | Hip BMD | mg/cm2 | Vit D2 + Ca | 12 | 123 | 851 | 127 | 0.5% | 0.3 | 0.3% | nd | NS
18410225 | Zhu, 2008 | Hip BMD | mg/cm2 | Ca | 12 | 133 | 826 | 129 | 0.2% | 0.2

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
18410225 | Zhu, 2008 | RCT | yes | yes | NA | yes | nd | yes | yes | no | yes | A
Adverse Event(s): ** | | | | | | There were no significant differences between the vitamin D and the control groups in the rate of incident cancer and vascular disease (ischemic heart disease and stroke). There were 8 and 5 adverse events in vitamin D and the control groups, respectively. One participant in the vitamin D group had mild asymptomatic hypercalcemia one occasion. No case of renal calculus was reported. 1 participant was deceased during the study.
Explanation for Overall Quality Grade (if not Grade A):

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse events.