# Evidence Tables: L-Q

## LaCroix, 2009

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
19221190 | LaCroix, 2009 | RCT-post hoc ** Case-cohort study | Postmenopausal women aged 50–79 years old. | A predicted survival of less than 3 years; a history of renal calculi or hypercalcemia; or current use of oral corticosteroids or calcitriol, or daily use of 600 IU or more of supplemental vitamin D | 1993–1998 | WHI | National Heart, Lung and Blood Institute | JHL

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
19221190 | LaCroix, 2009 | RCT-post hoc ** Case-cohort study | 40 US clinical centers | For RCT, 36,282 women; 18,176 (intervention), 18,106 (control) | For case-cohort study, 323 (cases) and 1962 (controls) | 62.4 (nd) | 50–79 years | 0% | White 83.1% Black 9.1% Hispanic 4.2% American Indian/Native American 0.4% Asian/Pacific Islander 2.0% Unknown 1.2% | BMI 29.1 (5.9) | nd | Low Ca intakes (<800mg/d) 34%

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed information as possible on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
19221190 | LaCroix, 2009 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | DiaSorin Liaison chemiluminescent immunoassay | nd | nd | nd | nd
19221190 | LaCroix, 2009 | Dietary calcium intake | nd | nd | nd | nd | nd | | nd | Daily total calcium, mg CaD arm 1148.4 (654.2) Placebo arm 1154.3 (658.0)

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
19221190 | LaCroix, 2009 | Ca+VitD | 500mg calcium carbonate + 200IU vitD3 (by Glaxo SmithKline, Pittsburgh, PA) | 1000mg calcium carbonate + 400IU vitD3 | Average 7 years | 2 times a day
19221190 | LaCroix, 2009 | Placebo
Co-intervention(s) * : | | | Hormone therapy and dietary modification was similar in both arms
Compliance/Adherence: | | | At trial closure, 76% of women enrolled were still taking study medications and 59% were taking at least 80% of study pills. Adherence was assessed by weighing returned pill bottles.

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
19221190 | LaCroix, 2009 | nd | Mortality | Causes of death were determined based on available medical records, autopsy reports, and the death certificate in a blinded fashion by local and central physician adjudicators.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
19221190 | LaCroix, 2009 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
19221190 | LaCroix, 2009 | Demographics (e.g., age, gender, race, education)? | Yes * | Age, race
19221190 | LaCroix, 2009 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No *
19221190 | LaCroix, 2009 | Medical conditions
19221190 | LaCroix, 2009 | Medication
19221190 | LaCroix, 2009 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | Yes | Latitude of clinical center, season of blood draw
19221190 | LaCroix, 2009 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | No *
19221190 | LaCroix, 2009 | Other | | CaD treatment assignment

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | Result | 95% CI | P btw
19221190 | LaCroix, 2009 | Total mortality (same as Wactawski-Wende 2006 [16481636]) | CaD | 84 mo | 744 | | HR | | | | 0.91 | 0.83–1.01
19221190 | LaCroix, 2009 | Total mortality (same as Wactawski-Wende 2006 [16481636]) | Placebo | 84 mo | 807 | | HR | | | | 0.91 | 0.83–1.01
19221190 | LaCroix, 2009 | CVD death | CaD | 84 mo | 226 | | HR | | | | 0.92 | 0.77–1.10
19221190 | LaCroix, 2009 | CVD death | Placebo | 84 mo | 244 | | HR | | | | 0.92 | 0.77–1.10
19221190 | LaCroix, 2009 | CHD death (same as Hsia 2007 [17309935] | CaD | 84 mo | 130 | | HR | | | | 1.01 | 0.79–1.29
19221190 | LaCroix, 2009 | CHD death (same as Hsia 2007 [17309935] | Placebo | 84 mo | 128 | | HR | | | | 1.01 | 0.79–1.29
19221190 | LaCroix, 2009 | Cerebrovascular death | CaD | 84 mo | 54 | | HR | | | | 0.89 | 0.62–1.29
19221190 | LaCroix, 2009 | Cerebrovascular death | Placebo | 84 mo | 60 | | HR | | | | 0.89 | 0.62–1.29
19221190 | LaCroix, 2009 | Cancer death (same as Wactawski-Wende 2006 [16481636]) | CaD | 84 mo | 344 | | HR | | | | 0.89 | 0.77–1.03
19221190 | LaCroix, 2009 | Cancer death (same as Wactawski-Wende 2006 [16481636]) | Placebo | 84 mo | 382 | | HR | | | | 0.89 | 0.77–1.03

* Example: OR Ca/placebo

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non-cases/Total N ** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
19221190 | LaCroix, 2009 | Total mortality | Tertiles of serum 25(OH)D, nmol/L | ≥52.5 | | | | 84 mo | Adjusted | OR | 1.00
| | | | 35.4–52.4 | | | | 84 mo | | | 1.42 | 1.06–1.91
| | | | <35.4 | | | | 84 mo | | | 1.46 | 1.07–1.99

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
19221190 | LaCroix, 2009 | Mortality | (Nested case-control study) Compared with women in the highest tertile of serum 25(OH)vitD, there was a significantly increased risk for death for women in the middle and low tertiles. The odds ratio for serum 25(OH)D level was analyzed as a continuous variable was 0.80 (95% CI, 0.67–0.95) for a difference of 29.9 nmol/L (the interquartile range).

Subgroup Analyses

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison* | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison* | Result | 95% CI | P btw | Result | 95% CI | P btw
Participants younger than 70 years
19221190 | LaCroix, 2009 | Total mortality | CaD | 85.2 mo | 466 | | HR | | | | 0.89 | 0.79–1.01
19221190 | LaCroix, 2009 | Total mortality | Placebo | 85.2 mo | 517 | | HR | | | | 0.89 | 0.79–1.01
19221190 | LaCroix, 2009 | CVD death | CaD | 85.2 mo | 115 | | HR | | | | 0.85 | 0.66–1.08
19221190 | LaCroix, 2009 | CVD death | Placebo | 85.2 mo | 135 | | HR | | | | 0.85 | 0.66–1.08
19221190 | LaCroix, 2009 | CHD death | CaD | 85.2 mo | 70 | | HR | | | | 0.99 | 0.71–1.38
19221190 | LaCroix, 2009 | CHD death | Placebo | 85.2 mo | 70 | | HR | | | | 0.99 | 0.71–1.38
19221190 | LaCroix, 2009 | Cerebrovascular death | CaD | 85.2 mo | 21 | | HR | | | | 0.62 | 0.36–1.08
19221190 | LaCroix, 2009 | Cerebrovascular death | Placebo | 85.2 mo | 33 | | HR | | | | 0.62 | 0.36–1.08
19221190 | LaCroix, 2009 | Cancer death | CaD | 85.2 mo | 245 | | HR | | | | 0.91 | 0.76–1.08
19221190 | LaCroix, 2009 | Cancer death | Placebo | 85.2 mo | 268 | | HR | | | | 0.91 | 0.76–1.08
Participants 70 or older
19221190 | LaCroix, 2009 | Total mortality | CaD | 80.4 mo | 278 | | HR | | | | 0.95 | 0.80–1.12
19221190 | LaCroix, 2009 | Total mortality | Placebo | 80.4 mo | 290 | | HR | | | | 0.95 | 0.80–1.12
19221190 | LaCroix, 2009 | CVD death | CaD | 80.4 mo | 111 | | HR | | | | 1.01 | 0.78–1.32
19221190 | LaCroix, 2009 | CVD death | Placebo | 80.4 mo | 109 | | HR | | | | 1.01 | 0.78–1.32
19221190 | LaCroix, 2009 | CHD death | CaD | 80.4 mo | 60 | | HR | | | | 1.02 | 0.71–1.47
19221190 | LaCroix, 2009 | CHD death | Placebo | 80.4 mo | 58 | | HR | | | | 1.02 | 0.71–1.47
19221190 | LaCroix, 2009 | Cerebrovascular death | CaD | 80.4 mo | 33 | | HR | | | | 1.20 | 0.72–2.01
19221190 | LaCroix, 2009 | Cerebrovascular death | Placebo | 80.4 mo | 27 | | HR | | | | 1.20 | 0.72–2.01
19221190 | LaCroix, 2009 | Cancer death | CaD | 80.4 mo | 99 | | HR | | | | 0.86 | 0.65–1.12
19221190 | LaCroix, 2009 | Cancer death | Placebo | 80.4 mo | 114 | | HR | | | | 0.86 | 0.65–1.12

Please copy the appropriate table above for all subgroup analyses of interest.

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
19221190 | LaCroix, 2009 | RCT-Parallel | y | y | n | y | nd | y | y | y | y | B
Adverse Event(s): ** | | | | | | Nd (Study pills were discontinued if women reported kidney stones, hypercalcemia, dialysis, or the use of calcitriol or daily supplements of more than 1,000 IU of vitamin D during semiannual contacts.)
Explanation for Overall Quality Grade (if not Grade A): | | | | | | It was the consensus among the Tufts EPC that overall, the methodological quality of the trial was B, particularly when the trial is being used to guide decisions about DRI, as opposed to decisions about whether to actively recommend supplementation for an individual woman.

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT– Parallel, RCT– Cross-over, RCT– Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse events.

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Poupulation | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
19221190 | LaCroix, 2009 | a) Eligibility criteria clear? (y/n) | y | a) Exposure assessor blinded to outcome info? (y/n) | nd | a) Method reported? (y/n) | n | a) One of the prespecified methods *** was used? (y/n) | y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | n | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | n | a) Clear definition of outcome, including time of ascertainment? (y/n) | y | a) Prospective collection of data? (y/n) | y
19221190 | LaCroix, 2009 | b) Sampling of population random or consecutive? (y/n) | y | b) Outcome assessor blinded to exposure measurement? (y/n) | y | b) Food composition database or suppl composition reported? (y/n) | nd | Time from sample collection to sample analysis reported? (y/n) | n | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | n | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | n | b) Loss to follow-up <20%? (y/n) | y | b) Analysis was planned when cohort was formed? (y/n) | n
19221190 | LaCroix, 2009 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | nd | | | | | b) Justification of final adjusted model selection? (y/n) | n | c) Do the authors specify a primary outcome? (y/n) | y | c) Justification of sample size (includes sample size calculations)? (y/n) | n
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Reporting quality was poor overall. Comparative categories were not clear in the results section. Matching factors were not reported in case and control groups.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Lappe 2004

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
15354150 | Lappe 2004 | RCT-post hoc | girl scouts | significant health problems (see list in paper); usual dietary calcium intake >1100 mg; BMI ≥85%tile for age and sex; participants in organized team sports ≥3x/wk | nd | - | Natl Institute of Nursing | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
15354150 | Lappe 2004 | RCT-post hoc | Omaha, NE 41 N | 63 | 59 | 9.5 | nd | 0 | 95% white 5% black | BMI 17 | nd | dietary intake calcium: 819 mg/d; vit D 4.5 μg/d

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
15354150 | Lappe 2004 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | | | | | dietary vit D 4.5 μg/d
| | Dietary calcium intake | 3-d food records | nd | n | | | | | dietary intake calcium: 819 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
15354150 | Lappe | calcium enriched diet | foods, calcium-fortified foods (but no calcium supplement) | ≥1500 mg/d | 24 mo | nd
| | usual diet
Co-intervention(s) * :
Compliance/Adherence: | | | nd

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
15354150 | Lappe | secondary | change in BMI
| | | change in wt
| | | change in ht

UI | Author Year | Comments
15354150 | Lappe | study funded the calcium enriched foods

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
15354150 | Lappe | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes | baseline wt, energy and protein intake
15354150 | Lappe | Demographics (e.g., age, gender, race, education)? | No
15354150 | Lappe | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | wt; ht
15354150 | Lappe | Medical conditions
15354150 | Lappe | Medication
15354150 | Lappe | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
15354150 | Lappe | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | physical activity
15354150 | Lappe | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline CI/SE/SD * | Final or Delta ** | Final or Delta CI/SE/SD * | Net difference | Net difference CI/SE/SD * | P between
15354150 | Lappe | BMI | kg/m2 | calcium enriched | 24 mo | 27 | 17 | 2.0 | 19 | 2.8 | | | NS
15354150 | Lappe | BMI | kg/m2 | usual | | 32 | 17 | 3.0 | 19 | 3.3
| | wt | kg | calcium enriched | 24 mo | 27 | 32.2 | 4.6 | 42.9 | 7.5 | | | NS
| | wt | kg | usual | | 32 | 33.2 | 6.7 | 44.1 | 9.9
| | ht | cm | calcium enriched | 24 mo | 27 | 137 | 6.3 | 151 | 7.0 | | | NS
| | ht | cm | usual | | 32 | 138 | 4.6 | 151 | 6.0

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−” sign: e.g. +2.8 or −2.8

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
15354150 | Lappe | ANCOVA with tertile of calcium intake (lowest (731±105 mg/d) vs. highest (1366±193 mg/d); baseline wt; mean energy and protein intake in 24 mo) on change in body wt | calcium was not a significant predictor
| | ANCOVA with tertile of calcium intake (lowest (731±105 mg/d) vs. highest (1366±193 mg/d); baseline wt; mean energy and protein intake in 24 mo) on change in ht | calcium was not a significant predictor

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
15354150 | Lappe | RCT post- hoc | nd | nd | NA | Y | N | N | N | Y | Y | B
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | did not account for all relevant variables like Tanner stage, menstrual history

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT– Parallel, RCT– Cross-over, RCT– Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Lappe 2007

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17556697 | Lappe 2007 | RCT | >55 y women; no cancer; mentally and physically fit to permit 4 y participation. More detailed inclusion criteria were published in a previous publication (Lappe 2006): women needed to be at least four years past last menses, in generally good health, living independently in the community, and weighing less than 300 pounds | More detailed inclusion criteria were published in a previous publication (Lappe 2006): 1) a medical diagnosis of any CKD, 2) Paget’s or other metabolic bone disease, and 3) history of cancer except for a) superficial basal or squamous cell carcinoma of the skin and b) other malignancies treated curatively more than 10 years prior to entry into study. | nd | none | nd | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
17556697 | Lappe 2007 | RCT | Nebraska, 41.4º N | 1180 | 1179 | 67 (7.3) | nd | 0 | white | BMI 29 | mentally and physically fit to permit 4 y participation | baseline 25(OH)- D 71.8 ± 20.3 nmol/L

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
17556697 | Lappe 2007 | 25(OH)D | | | | RIA | n | nd | nd | baseline 25(OH)D 71.8 ± 20.3 nmol/L
| | Dietary calcium intake

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
17556697 | Lappe 2007 | placebo | | placebo | 4 y(?) | nd
| | calcium only | | calcium citrate (1400 mg Ca/d) or calcium carbonate (1500 mg Ca/d) plus a vit D placebo | 4 y(?) | nd
| | calcium plus vit D | | calcium citrate (1400 mg Ca/d) or calcium carbonate (1500 mg Ca/d) plus 1000 IU (25μg) cholecalciferol (vit D3) | 4 y(?) | nd
Co-intervention(s) * : | | | nd
Compliance/Adherence: | | | nd

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17556697 | Lappe 2007 | secondary | incident cancer | from medical record (including breast, colon, lung, lymph, uterus and others)

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17556697 | Lappe 2007 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
17556697 | Lappe 2007 | Demographics (e.g., age, gender, race, education)? | no *
17556697 | Lappe 2007 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no *
17556697 | Lappe 2007 | Medical conditions
17556697 | Lappe 2007 | Medication
17556697 | Lappe 2007 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
17556697 | Lappe 2007 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no *
17556697 | Lappe 2007 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Event * | Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
17556697 | Lappe 2007 | incident cancer (years 1–4) | placebo | | | 20 | 288 | | % | 6.9% | | chi2=7.3 with df 2; P<0.03 comparing placebo with the other 2 groups
| | | calcium only | | | 17 | 445 | | | 3.8%
| | | calcium plus vit D | | | 13 | 446 | | | 2.9%
| | incident cancer (years 2–4) | placebo | | | 16 | 266 | | | 6.8%
| | | calcium only | | | 15 | 416 | | | 3.6%
| | | calcium plus vit D | | | 6 | 403 | | | 2.0%
| | incident cancer (years 1–4) | placebo | | | 20 | 288 | | RR | 1.0
| | | calcium only | | | 17 | 445 | | | 0.532 | 0.27–1.03 | 0.063
| | | calcium plus vit D | | | 13 | 446 | | | 0.402 | 0.20–0.82 | 0.013
| | incident cancer (years 2–4) | placebo | | | 18 | 266 | | | 1.0
| | | calcium only | | | 15 | 416 | | | 0.587 | 0.29–1.21 | 0.147
| | | calcium plus vit D | | | 8 | 403 | | | 0.232 | 0.09–0.60 | <0.005

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

≥2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure Category/Intervention Group | Crude or Adjusted analysis? | Mean Follow-up (months) | No. Analyzed | Baseline | Baseline SD * | Final or Delta ** | Final SD * | Net difference *** | Net difference SD * | P between groups ***
17556697 | Lappe 2007 | change in 25 OH(D) level at 12 mo | | placebo | | 12 mo | nd | 72.1 | 20.7 | 71.1 | 19.8 | −0.23 | 14.7 | nd
| | | | calcium only | | | | 71.6 | 20.5 | 71 | 20.3 | −0.74 | 13.0
| | | | calcium plus vit D | | | | 71.8 | 20.0 | 96.0 | 21.4 | 23.9 | 17.8

Duplicate one row per exposure category or intervention group. Please write “nd” if there was no data reported. DO NOT LEAVE BLANK.

* Please choose one and delete the others

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “− “ sign: e.g. +2.8 or −2.8

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
17556697 | Lappe 2007 | cancer risk | Logistic regression showed treatment assignment and either baseline or 12 mo 25()H)-D levels were significant independent predictors (P<0.002, P<0.03) respectively.
| | | RR of cancer per unit concentration of 25(OH)D was 0.983 (CI 0.968 to 0.997); P<0.01
| | renal calculi in placebo | 1/288
| | renal calculi in calcium only | 3/445
| | renal calculi in calcium plus vit D | 1/446

UI | Author Year | Comments for Results
17556697 | Lappe 2007 | unclear reporting, discrepancy between Table 1 and text

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
17556697 | Lappe 2007 | RCT - parallel | Y | N | NA | Y | N | Y | N | NA | N | B
Adverse Event(s): ** | | | | | | renal calculi (see above), no significant difference between groups
Explanation for Overall Quality Grade (if not Grade A): | | | | | | unclear reporting, discrepancy between Table 1 and text

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Lappe 2008

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
18433305 | Lappe 2008 | RCT | Women entered basic training at the US Navy | nd | May 2001 to march 2006 | nd | Department of Defense Bone Health and Military Readiness Grant | MC

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
18433305 | Lappe 2008 | RCT | Great Lakes, IL, USA 41° North | 5201 | 3700 | Median: 19 | 17–35 | 0 | American Indian: 3%, Asian: 4%, non- Hispanic black: 18%, Hispanic: 13%, non- Hispanic white: 54%, other: 4% | Mean BMI = 24 (ranged 15–43) | Assumed healthy (Navy recruits) | Mean dairy servings/wk = 6 (ranged 1–26)

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
18433305 | Lappe 2008 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | | | | Very little cutaneous conversion of vitamin D takes place between the months of September and March due to the latitude.
18433305 | Lappe 2008 | Dietary calcium intake | Risk factor questionnaire (no further information) | nd | n | | | | | Mean dairy servings/wk = 6 (ranged 1–26)

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
18433305 | Lappe 2008 | Calcium + vitamin D | nd | 200 mg calcium and 800 IU vitamin D/day | 8 weeks | 4 supplement pills per day made available in galley line at breakfast and dinner
| | placebo
Co-intervention(s) * : | | | none
Compliance/Adherence: | | | To monitor pill taking, project staff observed the galley food lines, visited recruits in their quarters, and conducted an exit interview.

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
18433305 | Lappe 2008 | primary | stress fractures | Stress fractures were ascertained when recruits reported to the Great lakes clinic with symptoms. All stress fractures were confirmed with radiography or technetium scan according to the usual Navy protocol.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
18433305 | Lappe 2008 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
18433305 | Lappe 2008 | Demographics (e.g., age, gender, race, education)? | Yes | Age group (<25 vs. >=25 yr)
18433305 | Lappe 2008 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no
18433305 | Lappe 2008 | Medical conditions
18433305 | Lappe 2008 | Medication | Use of depomedroxyprogesterone
18433305 | Lappe 2008 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
18433305 | Lappe 2008 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | exercise sessions/wk (high vs. low), smoking, run time per 1.5 mi at entry of basic training
18433305 | Lappe 2008 | Other | Menses during training

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | Result | 95% CI | P btw
18433305 | Lappe 2008 | Stress fracture (ITT analysis) | Calcium + vitamin D | 2 | 5.3% | 2626 | RR ca+vitD/placebo | 0.8 | 0.64–0.99 | 0.026
18433305 | Lappe 2008 | Stress fracture (ITT analysis) | Placebo | 2 | 6.6% | 2575 | RR ca+vitD/placebo | 0.8 | 0.64–0.99 | 0.026
18433305 | Lappe 2008 | Stress fracture (per protocol analysis) | Calcium + vitamin D | 2 | 6.8% | 1852 | OR ca+vitD/placebo | nd | | 0.02 | 0.789 | 0.616–1.01 | 0.0589
18433305 | Lappe 2008 | Stress fracture (per protocol analysis) | Placebo | 2 | 8.6% | 1848 | OR ca+vitD/placebo | nd | | 0.02 | 0.789 | 0.616–1.01 | 0.0589

* Example: OR Ca/placebo

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
18433305 | Lappe 2008 | RCT - parallel | Y | nd | NA | N | nd | Y | Y | Y | Y | B
Adverse Event(s): ** | | | | | | GI disruption such as constipation, diarrhea, upset stomach (4%), and musculoskeletal soreness (0.9%)
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Dropout rate = 29% (majority withdrew because the participants changed their mind, forgot, it was too difficult, or for no reported reason). Participants who developed adverse events also withdrew from the study. A little bit more people allocated to treatment group withdrew than the placebo group (n=774 vs. 727 respectively). There was ITT analysis but multivariate model only for per protocol analysis.

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Larsson 2006

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
16522915 | Larsson 2006 | Cohort study | - Men aged 45-79; - Resides in Vastmanland & Orebro counties (n=100303); - Completed the questionnaire (n=48850) | - Missing/erroneous registration #; - Implausibly high energy intake; - Previous cancer (excl. nonmelanoma skin cancer) at baseline | 1997 (Autumn) | The Cohort of Swedish Men | the Swedish Cancer Foundation, the Swedish Research Council-Longitudinal Studies, the Swedish Foundation for International Cooperation in Research and Higher Education (STINT), Vastmanland County Research Fund against Cancer, Orebro County Council Research Committee, And Orebro Medical Center Research Foundation | TTe

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
16522915 | Larsson 2006 | Cohort study | Sweden (Vastmanland [59° 37′N] & Orebro counties [59.23 N]) | 48850 | 45306 | 60.3 (nd) | | 100% | nd | BMI=25.8kg/m2 | Hx of DM=6.1% Aspirin use=36.4% | Vit D=6.4 μg/d Saturated fat 33.5 g/d Ca=809-1665 mg/d

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
16522915 | Larsson 2006 | Dietary calcium intake | FFQ | Swedish Food Administration Database (Bergstrom 1991) | Yes: by 24HR and correlation coefficient=0.77 (total and dietary calcium intake) | NA | NA | | nd | Ca=809–1665 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
16522915 | Larsson 2006 | Not explicitly described | Colorectal caner | National Swedish Cancer Register (-12/31/2003) and Regional Cancer Register covering the study area (from 1/1/2004-12/31/2004), only adenocarcinoma.
16522915 | Larsson 2006 | Not explicitly described | Colon caner | National Swedish Cancer Register (-12/31/2003) and Regional Cancer Register covering the study area (from 1/1/2004-12/31/2004), only adenocarcinoma.
16522915 | Larsson 2006 | Not explicitly described | Rectal caner | National Swedish Cancer Register (-12/31/2003) and Regional Cancer Register covering the study area (from 1/1/2004-12/31/2004), only adenocarcinoma. (Rectal cancers included tumors in the rectosigmoid junction and rectum.)
16522915 | Larsson 2006 | Not explicitly described | Proximal colon caner | National Swedish Cancer Register (-12/31/2003) and Regional Cancer Register covering the study area (from 1/1/2004-12/31/2004), only adenocarcinoma. (proximal colon cancers defined as tumors occurring from the cecum to the splenic flexure)
16522915 | Larsson 2006 | Not explicitly described | Distal colon caner | National Swedish Cancer Register (-12/31/2003) and Regional Cancer Register covering the study area (from 1/1/2004-12/31/2004), only adenocarcinoma. (distal colon cancers defined as tumors occurring in the splenic flexure, descending colon, and sigmoid colon)

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
16522915 | Larsson 2006 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes (multivitamin, total energy, saturated fat, read meat, fruit, vegetables)
16522915 | Larsson 2006 | Demographics (e.g., age, gender, race, education)? | Yes (age, education)
16522915 | Larsson 2006 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes (BMI)
16522915 | Larsson 2006 | Medical conditions | Yes (family Hx, Hx of DM)
16522915 | Larsson 2006 | Medication | Yes (Aspirin)
16522915 | Larsson 2006 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | No
16522915 | Larsson 2006 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes (exercise, smoking, alcohol
16522915 | Larsson 2006 | Other | nd

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean follow- up, mo | Mean Ca dose | No. of Cases (Event) * | No. of total subjects ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups *** | P for trend ****
16522915 | Larsson 2006 | Colorectal cancer (total Ca intake [mg]) | Q1 | 80.4 | <956 | 127 | 11348 | Adj (age) | RR (HR) | 1.0 | Ref | Nd | 0.03
| | | Q2 | 80.4 | 956-1179 | 111 | 11341 | | | 0.81 | 0.63-1.04 | Nd
| | | Q3 | 80.4 | 1180-1444 | 107 | 11295 | | | 0.77 | 0.59-0.99 | Nd
| | | Q4 | 80.4 | 1445- | 104 | 11322 | | | 0.73 | 0.51-0.91 | Nd
16522915 | Larsson 2006 | Colorectal cancer (total Ca intake [mg]) | Q1 | 80.4 | <956 | 127 | 11348 | Adj (full multivariate model) | RR (HR) | 1.0 | Ref | Nd | 0.01
| | | Q2 | 80.4 | 956-1179 | 111 | 11341 | | | 0.80 | 0.61-1.04 | Nd
| | | Q3 | 80.4 | 1180-1444 | 107 | 11295 | | | 0.73 | 0.56-0.96 | Nd
| | | Q4 | 80.4 | 1445- | 104 | 11322 | | | 0.68 | 0.51-0.91 | Nd
16522915 | Larsson 2006 | Colon cancer (total Ca intake [mg]) | Q1 | 80.4 | <956 | 77 | 11348 | Adj (age) | RR (HR) | 1.0 | Ref | Nd | 0.24
| | | Q2 | 80.4 | 956-1179 | 62 | 11341 | | | 0.74 | 0.53-1.04 | Nd
| | | Q3 | 80.4 | 1180-1444 | 70 | 11295 | | | 0.84 | 0.60-1.16 | Nd
| | | Q4 | 80.4 | 1445- | 67 | 11322 | | | 0.78 | 0.56-1.08 | Nd
16522915 | Larsson 2006 | Colon cancer (total Ca intake [mg]) | Q1 | 80.4 | <956 | 77 | 11348 | Adj (full multivariate model) | RR (HR) | 1.0 | Ref | Nd | 0.15
| | | Q2 | 80.4 | 956-1179 | 62 | 11341 | | | 0.72 | 0.51-1.01 | Nd
| | | Q3 | 80.4 | 1180-1444 | 70 | 11295 | | | 0.80 | 0.57-1.12 | Nd
| | | Q4 | 80.4 | 1445- | 67 | 11322 | | | 0.72 | 0.50-1.04 | Nd
16522915 | Larsson 2006 | Rectal cancer (total Ca intake [mg]) | Q1 | 80.4 | <956 | 50 | 11348 | Adj (age) | RR (HR) | 1.0 | Ref | Nd | 0.05
| | | Q2 | 80.4 | 956-1179 | 49 | 11341 | | | 0.91 | 0.61-1.36 | Nd
| | | Q3 | 80.4 | 1180-1444 | 37 | 11295 | | | 0.67 | 0.44-1.02 | Nd
| | | Q4 | 80.4 | 1445- | 37 | 11322 | | | 0.69 | 0.45-1.06 | Nd
16522915 | Larsson 2006 | Rectal cancer (total Ca intake [mg]) | Q1 | 80.4 | <956 | 50 | 11348 | Adj (full multivariate model) | RR (HR) | 1.0 | Ref | Nd | 0.02
| | | Q2 | 80.4 | 956-1179 | 49 | 11341 | | | 0.91 | 0.61-1.37 | Nd
| | | Q3 | 80.4 | 1180-1444 | 37 | 11295 | | | 0.63 | 0.40-0.98 | Nd
| | | Q4 | 80.4 | 1445- | 37 | 11322 | | | 0.61 | 0.38-0.98 | Nd

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = -6; group 1 vs. 2 = -8

**** P value for testing the linear trend of the OR/RR across different categories or doses

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
16522915 | Larsson 2006 | Results also on proximal and distal colon cancer subsites # Multivariate RRs were adjusted for age (in mo), education (less than high school, high school graduate, or more than high school), family history of colorectal cancer (yes or no), BMI (in kg/m2; <23.0, 23.0–24.9, 25.0–29.9, or >30.0), exercise (h/wk; 3 categories), history of diabetes (yes or no), cigarette smoking (never, past, or current), aspirin use (no, <10 y, or >10 y), multivitamin supplement use (no, occasional use, or regular use), total energy intake (continuous), and quartiles of saturated fat, total vitamin D, alcohol, fruit, vegetable, and red meat intakes. ## Sensitivity analysis of colorectal cancer #1 (excluding the participants with Ca intake >2500 mg/d): multivariate Trend P=0.006 ### Sensitivity analysis of colorectal cancer #2 (excluding the cases developed cancer within the first two years of follow-up): multivariate Trend P=0.005 #### Data on similar outcomes on dietary calcium only not analyzed because only 2.1% of participants were supplemental user, precluding meaningful analyses. ##### Data on similar outcomes on dairy foods presented but not extracted.

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
16522915 | Larsson 2006 | a) Eligibility criteria clear? (y/n) | n/nd | a) Exposure assessor blinded to outcome info? (y/n) | Nd | a) Method reported? (y/n) | y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | a) Clear definition of outcome, including time of ascertainment? (y/n) | y | a)Prospective collection of data? (y/n) | y
16522915 | Larsson 2006 | b) Sampling of population random or consecutive? (y/n) | N (~50%) | b) Outcome assessor blinded to exposure measurement? (y/n) | Nd | b) Food composition database or suppl composition reported? (y/n) | y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | b) Loss to follow-up <20%? (y/n) | y/nd | b) Analysis was planned when cohort was formed? (y/n) | n
16522915 | Larsson 2006 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | y | | | | | b) Justification of final adjusted model selection? (y/n) | n | c) Do the authors specify a primary outcome? (y/n) | n | c) Justification of sample size (includes sample size calculations)? (y/n) | n
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Some limited reporting (inclusion and blinding), post-hoc analysis of a database; cases not confirmed by pathology results

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Larsson 2008

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
18332289 | Larsson 2008 | Cohort Study | Male smokers, 50–69 y | Nonmelanoma cancer, other serious disease, anticoagulant therapy, excessive doses of vitamin E, vitamin A, beta carotene, incomplete dietary data, self-reported history of stroke | 1985–1988 | ATBC study | Gov’t | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
18332289 | Larsson 2008 | Cohort Study | Southwestern Finland ~60° | 26556 | 26556 | ~57 (nd) | 50–69 | 100 | Mostly white (implied) | ~26.5 | Healthy | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
18332289 | Larsson 2008 | Dietary calcium intake | FFQ | nd | “evaluated previously” | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
18332289 | Larsson 2008 | 1° | First stroke (and subtypes) | Hospital discharge and death registries, by ICD codes. Subtypes confirmed in a sample, correct between 79 & 95% of time.
| | | Cerebral infarction included here
| | | Also separate analysis for much smaller numbers of cases of intracerebral hemorrhage and subarachnoid hemorrhage. Not extracted here.
| | | No analysis of total stroke.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
18332289 | Larsson 2008 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes | Total energy intake
18332289 | Larsson 2008 | Demographics (e.g., age, gender, race, education)? | Yes | Age
18332289 | Larsson 2008 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI
18332289 | Larsson 2008 | Medical conditions | Yes | DM, CHD
18332289 | Larsson 2008 | Medication | Yes | Alpha tocopherol and beta carotene
18332289 | Larsson 2008 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | No
18332289 | Larsson 2008 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | # cigarettes, physical activity, EtOH
18332289 | Larsson 2008 | Other | Yes | BP, total cholesterol, HDL

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Median Ca intake | No. of Cases (Event) * | Total N ** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups *** | P for trend ****
18332289 | Larsson 2008 | Cerebral infarction | Total Ca intake Quintile 1 | | 876 | 518 | ~5311 | 13.6 years | Adjusted (“multivariate”) | RR | 1.00 | -- | -- | 0.09
| | | Quintile 2 | | 1178 | 541 | ~5311 | | | | 1.08 | 0.95, 1.22 | NS
| | | Quintile 3 | | 1379 | 542 | ~5311 | | | | 1.09 | 0.96, 1.23 | NS
| | | Quintile 4 | | 1581 | 546 | ~5311 | | | | 1.11 | 0.98, 1.26 | NS
| | | Quintile 5 | | 1916 | 555 | ~5311 | | | | 1.10 | 0.98, 1.26 | NS

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
18332289 | Larsson 2008 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | nd | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
18332289 | Larsson 2008 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
18332289 | Larsson 2008 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Outcome ascertainment questionable; did not confirm diagnosis in most. In sample, large percentage with misclassification of stroke (correct in 79–90%) and stroke death (correct in 91–95%).

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Larsson 2009

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
19056569 | Larsson 2009 | Cohort study | -Women born between 1917 and 1948 in Vastmanland County, Sweden -Women born between 1914 and 1948 in Uppsala County, Sweden | -erroneous or missing national registration number -questionnaires that lacked a date, the date the subject moved out of study area, or date of death -implausible values for energy intake -cancer diagnosis except non- melanoma skin cancer | 1987–1990 | Swedish Mammography Cohort | Swedish Cancer Foundation, Swedish Research Council for Infrastructure | KP

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
19056569 | Larsson 2009 | Cohort study | Sweden 62ºN | 61,433 | 36,664 | 53.7(9.7) | Nd | 0 | Swedish | BMI 24.8(3.9) | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed information as possible on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data ...etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
19056569 | Larsson 2009 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | nd | nd | nd | nd
| | Dietary calcium intake | FFQ | Swedish National Food Administration Database | Y- Pearson correlation coefficient between FFQ and dietary records was 0.5 for dietary calcium, Spearman correlation coefficient between FFQ and fourteen 24-h recalls over 1 y was 0.77 for dietary and total calcium intake | nd | nd | | nd | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
19056569 | Larsson 2009 | Primary | Invasive breast cancer | Linkage with national and regional Swedish Cancer registers

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
19056569 | Larsson 2009 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Total energy intake, fiber
19056569 | Larsson 2009 | Demographics (e.g., age, gender, race, education)? | Yes | Age, education
19056569 | Larsson 2009 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI, height
19056569 | Larsson 2009 | Medical conditions | History of benign breast disease
19056569 | Larsson 2009 | Medication | Use of oral contraceptives, use of postmenopausal hormones
19056569 | Larsson 2009 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
19056569 | Larsson 2009 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | alcohol
19056569 | Larsson 2009 | Other | Age at first birth, age at menarche, age at menopause, family history of breast cancer

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non- cases/Total N ** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups *** | P for trend ****
19056569 | Larsson 2009 | Invasive breast cancer | Quintile 1: <727 mg/d calcium | nd | nd | 595 | nd | 9.4 yrs | Adjusted | RR | 1.00 | Reference | nd | 0.49
| | | Quintile 2: 727–862 mg/d calcium | nd | nd | 595 | nd | 9.4 yrs | | | 0.97 | 0.87–1.09 | nd
| | | Quintile 3: 863–980 mg/d calcium | nd | nd | 592 | nd | 9.4 yrs | | | 0.95 | 0.84–1.06 | nd
| | | Quintile 4: 980–1124 mg/d calcium | nd | nd | 571 | nd | 9.4 yrs | | | 0.93 | 0.83–1.04 | nd
| | | Quintile 5:≥1125 mg/d calcium | nd | nd | 599 | nd | 9.4 yrs | | | 0.97 | 0.87–1.09 | nd

Duplicate one row per exposure category or intervention group

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
19056569 | Larsson 2009 | a) Eligibility criteria clear? (y/n) | y | a) Exposure assessor blinded to outcome info? (y/n) | nd | a) Method reported? (y/n) | y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | a) Clear definition of outcome, including time of ascertainment? (y/n) | y | a) Prospective collection of data? (y/n) | y
19056569 | Larsson 2009 | b) Sampling of population random or consecutive? (y/n) | y | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | b) Loss to follow-up <20%? (y/n) | n | b) Analysis was planned when cohort was formed? (y/n) | nd
19056569 | Larsson 2009 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | y | | | | | b) Justification of final adjusted model selection? (y/n) | y | c) Do the authors specify a primary outcome? (y/n) | y | c) Justification of sample size (includes sample size calculations)? (y/n) | n
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): . | | | | | | | No data on blinding, almost half of original cohort didn’t answer second questionnaire for various reasons

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Li 2007

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
7388667 | Li 2007 | Case- cohort study | Male physicians | Hx of MI, stroke, hx of TIA, unstable angina, cancer (except nonmelanoma skin cancer), current renal or liver disease, pepticulcer, gout, current use of platelet-active agents, vit A or beta-carotene supplements | 1982 – 2000 | Physicians’ Health Study | NIH, US Army Medical Research | KP/SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
17388667 | Li 2007 | Case- cohort study | United States-multiple locations | 2684 | 1156 492 cases 664 control | 58.9±8.3 at study onset. 69.3±7.3 at diagnosis | nd | 100% | 6% not of European descent | Age at study onset: cases = 58.9(8.3), controls = 59.0(8.0) | nd | -Vit D deficiency (<20 ng/ml) in summer/fall: 10.8% in cases and 12.7% in controls -Vit D deficiency in spring/winter: 27.9% in cases and 36.4% in controls

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
17388667 | Li 2007 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | RIA | Yes: mean intra-pair coefficients of variation for blinded duplicate quality control samples were 7.9% to 8.1% for 25(OH)D and 1,25(OH)D | Nd | Spring or winter: 24.1% of cases and 26.0% of controls | nd
| | Dietary calcium intake | Nd | Nd | Nd | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17388667 | Li 2007 | secondary | Prostate cancer | Tumor Gleason score, grade, stage determined by reviewing medical and pathological reports

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must be explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
| | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
| | Demographics (e.g., age, gender, race, education)? | Yes | Age (matched), race
| | Anthropometrics (e.g., BMI, body weight, % body fat)? | No
| | Medical conditions
| | Medication
| | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location)
| | Smoking and other life styles variables | Yes | Smoking status (matched), exercise
| | Other | Follow-up period (matched)

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases* | No. of Non- cases | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups*** | P for trend****
17388667 | Li 2007 | Total prostate cancer | Quartile 1: lowest 25(OH)D | Nd | Nd | Nd | nd | adjusted | OR | 1.01 | 0.71–1.44 | nd | 0.91
| | | Quartile 2 | Nd | Nd | Nd | Nd | | | 1.26 | 0.89–1.80
| | | Quartile 3 | Nd | Nd | Nd | Nd | | | 1.00 | 0.71–1.41
| | | Quartile 4: highest 25(OH)D | nd | Nd | nd | Nd | | | Reference | Reference
| | Aggressive prostate cancer | Quartile 1: lowest 25(OH)D | Nd | Nd | Nd | nd | adjusted | OR | 1.27 | 0.76–2.13 | nd | 0.74
| | | Quartile 2 | Nd | Nd | Nd | Nd | | | 1.33 | 0.80–2.20
| | | Quartile 3 | Nd | Nd | Nd | Nd | | | 0.97 | 0.58–1.60
| | | Quartile 4: highest 25(OH)D | nd | Nd | nd | Nd | | | Reference | Reference
| | Total prostate cancer age >= 65 y | Quartile 1: lowest 25(OH)D | Nd | Nd | Nd | nd | adjusted | OR | 1.03 | 0.67–1.60 | nd | 0.95
| | | Quartile 2 | Nd | Nd | Nd | Nd | | | 1.32 | 0.86–2.03
| | | Quartile 3 | Nd | Nd | Nd | Nd | | | 1.02 | 0.68–1.54
| | | Quartile 4: highest 25(OH)D | nd | Nd | nd | Nd | | | Reference | Reference
| | Aggressive prostate cancer age >= 65 y | Quartile 1: lowest 25(OH)D | Nd | Nd | Nd | nd | adjusted | OR | 1.34 | 0.71–2.53 | nd | 0.68
| | | Quartile 2 | Nd | Nd | Nd | Nd | | | 1.41 | 0.75–2.62
| | | Quartile 3 | Nd | Nd | Nd | Nd | | | 0.91 | 0.49–1.70
| | | Quartile 4: highest 25(OH)D | nd | Nd | nd | Nd | | | Reference | Reference
| | Total prostate cancer | Quartile 1: lowest 1,25(OH)D | Nd | Nd | Nd | nd | adjusted | OR | 0.91 | 0.63–1.33 | nd | 0.74
| | | Quartile 2 | Nd | Nd | Nd | Nd | | | 1.35 | 0.95–1.92
| | | Quartile 3 | Nd | Nd | Nd | Nd | | | 0.94 | 0.66–1.36
| | | Quartile 4: highest 1,25(OH)D | nd | Nd | nd | Nd | | | Reference | Reference
| | Aggressive prostate cancer | Quartile 1: lowest 1,25(OH)D | Nd | Nd | Nd | nd | adjusted | OR | 1.37 | 0.81–2.33 | nd | 0.07
| | | Quartile 2 | Nd | Nd | Nd | Nd | | | 1.90 | 1.14–3.16
| | | Quartile 3 | Nd | Nd | Nd | Nd | | | 1.19 | 0.69–2.05
| | | Quartile 4: highest 1,25(OH)D | nd | Nd | nd | Nd | | | Reference | Reference
| | Total prostate cancer age >= 65 y | Quartile 1: lowest 1,25(OH)D | Nd | Nd | Nd | nd | adjusted | OR | 1.19 | 0.75–1.89 | nd | 0.26
| | | Quartile 2 | Nd | Nd | Nd | Nd | | | 1.53 | 0.98–2.39
| | | Quartile 3 | Nd | Nd | Nd | Nd | | | 1.17 | 0.73–1.89
| | | Quartile 4: highest 1,25(OH)D | nd | Nd | nd | Nd | | | Reference | Reference
| | Aggressive prostate cancer age >= 65 y | Quartile 1: lowest 1,25(OH)D | Nd | Nd | Nd | nd | adjusted | OR | 1.93 | 0.99–3.75 | nd | 0.03
| | | Quartile 2 | Nd | Nd | Nd | Nd | | | 2.17 | 1.15–4.10
| | | Quartile 3 | Nd | Nd | Nd | Nd | | | 1.55 | 0.76–3.16
| | | Quartile 4: highest 1,25(OH)D | nd | Nd | nd | Nd | | | Reference | Reference
| | Total prostate cancer | Low 25(OH)D, Low 1,25(OH)D | Nd | Nd | Nd | nd | adjusted | OR | 1.33 | 0.94–1.88 | nd | 0.85 (p- value for interaction)
| | | Low 25(OH)D, High 1,25(OH)D | Nd | Nd | Nd | nd | | | 1.16 | 0.82–1.64
| | | High 25(OH)D, Low 1,25(OH)D | | | | | | | | 0.85–1.70
| | | High 25(OH)D, High 1,25(OH)D | | | | | | | Reference | Reference
| | Aggressive prostate cancer | Low 25(OH)D, Low 1,25(OH)D | Nd | Nd | Nd | nd | adjusted | OR | 2.06 | 1.24–3.43 | nd | 0.23 (p- value for interaction)
| | | Low 25(OH)D, High 1,25(OH)D | Nd | Nd | Nd | nd | | | 1.08 | 0.66–1.77
| | | High 25(OH)D, Low 1,25(OH)D | | | | | | | 1.24 | 0.75–2.04
| | | High 25(OH)D, High 1,25(OH)D | | | | | | | Reference | Reference

UI | Author Year | Comments for Results
17388667 | Li 2007 | Cutoff points for quartiles were only listed for controls (presumably for total prostate cancer in all age groups); not for cases or for age or aggressive disease subgroups. Cutoffs for controls were 18.3, 24.4, and 31.1 ng/ml for winter/spring-collected samples and 24.4, 32.0, and 39.5 ng/ml for summer/fall-collected samples.

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
17388667 | Li 2007 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | Y | a) Method reported? (y/n) | NA | a) One of the prespecified methods was used? (y/n) | Y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
17388667 | Li 2007 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | Y | b) Food composition database or suppl composition reported? (y/n) | NA | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | nd
17388667 | Li 2007 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | NA | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): . | | | | | | | Thorough explanations of methodology, however group comparison data was not clearly documented with regards to group cutoffs. Only 492/1066 (46%) cases had vit D analysis because of limited funding

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

## Lijnen 1995

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
8557965 | Lijnen 1995 | RCT | Male, “Normal” Normotensive (not defined) | none | <1994 | None | nd Supplements provided by industry | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake...etc.)
8557965 | Lijnen 1995 | RCT | Leuven, Belgium 51° | 32 | 32 | 24±1 | 20–44 y | 100 | nd | Weight 75.9±1.3 Kg | Healthy | 1 month low Ca diet run-in

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | nd | nd | nd | nd
8557965 | Lijnen 1995 | Dietary calcium intake | None | NA | NA | | | | | “Low Ca diet” run-in

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
8557965 | Lijnen 1995 | Ca supplement | Ca gluconate | 2 g | 16 wk | 1 g 2x/day
| | Placebo
Co-intervention(s) * : | | | Low dairy diet
Compliance/Adherence: | | | nd

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
8557965 | Lijnen 1995 | 2° | SBP/DBP | Standing and supine
| | 2° | 25(OH)D | Competitive protein binding assay (Medgenix and/or Inestar Corp)
| | | 1,25(OH)D | Radioreceptor assay (Medgenix and/or Inestar Corp)

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
8557965 | Lijnen 1995 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
8557965 | Lijnen 1995 | Demographics (e.g., age, gender, race, education)? | No
8557965 | Lijnen 1995 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No
8557965 | Lijnen 1995 | Medical conditions
8557965 | Lijnen 1995 | Medication
8557965 | Lijnen 1995 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
8557965 | Lijnen 1995 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | No
8557965 | Lijnen 1995 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline SEM | Delta/~Final | Delta Range/~SEM | Net difference | Net difference CI/SE/SD * | P between
8557965 | Lijnen 1995 | SBP (standing) | mm Hg | Ca suppl | 4 | 16 | ~124 (figure) | ~2 (figure) | −7.8 | −16, +4 | −5.7 | | 0.01
8557965 | Lijnen 1995 | SBP (standing) | mm Hg | Placebo | | 16 | ~122 | ~2 | −2.1 | −15, +7
| | DBP (standing) | mm Hg | Ca suppl | 4 | 16 | ~78 | ~2 | −2.6 | −14, +6 | −3.5 | | 0.06
| | DBP (standing) | mm Hg | Placebo | | 16 | ~76 | ~2 | +0.9 | −4, +16
| | SBP (supine) | mm Hg | Ca suppl | 4 | 16 | 114 | 2 | ~110 | ~2 | ~−2 | | NS
| | SBP (supine) | mm Hg | Placebo | | 16 | 114 | 2 | ~112 | ~2
| | DBP (supine) | mm Hg | Ca suppl | 4 | 16 | 74 | 2 | ~73 | ~1 | ~−1 | | NS
| | DBP (supine) | mm Hg | Placebo | | 16 | 72 | 2 | ~72 | ~1
| | 25(OH)D | ng/mL | Ca suppl | 4 | 16 | ~24 | ~4 | ~20 | ~2 | ~+5 | | NS
| | 25(OH)D | ng/mL | Placebo | | 16 | ~29 | ~3 | ~21 | ~2
| | 1,25(OH)D | pg/mL | Ca suppl | 4 | 16 | ~30 | ~3 | ~21 | ~3 | ~−9 | | <0.05
| | 1,25(OH)D | pg/mL | Placebo | | 16 | ~31 | ~2 | ~31 | ~2

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−” sign: e.g. +2.8 or −2.8

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
8557965 | Lijnen 1995 | RCT | nd | nd | Y | Y | nd | Y | Y | N | N | C
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Incomplete data reporting. No data on background diet, even though diet was manipulated

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Lin 2005

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
15800268 | Lin 2005 | Cohort study Participants are included in an RCT | US female professionals aged 45 or older Free of cancer and CVD | Excluded (n=2900); - did not provide sufficient dietary information at baseline; - had an implausible total energy intake (<600 or >3,500 kcal/day); - failed to provide information on potential risk factors at baseline | 1993 (RCT) | The Women’s Health Study (a 2x2 factorial RCT evaluating low-dose ASA and Vit E for the primary prevention of cancer and CVD. | NCI and National Heart, Lung, and Blood Institute | TTe

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake...etc.)
15800268 | Lin 2005 | Cohort study Participants are included in an RCT | US (25° 46′–54° 40′) | 36976 | 36976 | Nd (~54 y) | 45 or over (enrollment of the RCT) | 0% | nd | BMI=~26 | FH of colorectal cancer=~10% Previous colorectal polyps=~3% Current use of hormone replacement=~40% Physical activity=~ 1300kcal/d | Total energy intake=~1700 kcal/d Total fat intake=~55 g/d Total fiber intake=~20 g/d Total Ca=882 mg/d (median) Total Vit D=205 IU/d (median)

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | nd | nd | nd | nd
15800268 | Lin 2005 | Dietary calcium intake | FFQ | USDA + data from manufacturers | Correlation coefficients (FFQ and 4 1-week records): 0.56 (total Ca) and 0.51 (dietary Ca) | | | | | 882 mg/d (median)

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
15800268 | Lin 2005 | nd | Colorectal cancer | Follow-up questionnaire (q6mo for the 1 ^ st ^ y and annually thereafter) confirmed by medical records and pathology reports during a follow-up of 9 y.
| | nd | Proximal colon cancer | Not fully defined (data not extracted)
| | nd | Distal colon cancer | Not fully defined (data not extracted)

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
15800268 | Lin 2005 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes (multivitamin, saturated fat, red meat, total energy intake)
15800268 | Lin 2005 | Demographics (e.g., age, gender, race, education)? | Yes (age)
15800268 | Lin 2005 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes (BMI)
15800268 | Lin 2005 | Medical conditions | Yes (family history, polyps)
15800268 | Lin 2005 | Medication | Yes (hormone replacement therapy)
15800268 | Lin 2005 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | No
15800268 | Lin 2005 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes (physical activity, smoking, alcohol)
15800268 | Lin 2005 | Other | Yes (RCT arms [aspirin/no, Vit E/not])

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

# first model used only age and RCT assignments (aspirin & Vit E)

# second model used the full multivariate model

# performed a sensitivity analysis by excluding cases developed colorectal cancer during the first year of follow-up and added symptomatic examination, and regular screening test of colorectal cancer [colono- or sigmoidoscopy] to the second model.

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Total N ** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups *** | P for trend ****
15800268 | Lin 2005 | Colorectal cancer (total Ca [mg]) | Q1 | Nd | <614 | 41 | 7691 | 10 y (120 mo) | Adj (first model) | RR (HR) | 1.0 | Ref | nd | 0.17
| | | Q2 | Nd | 614–<785 | 31 | Nd | | | | 0.74 | 0.46–1.18 | Nd
| | | Q3 | Nd | 785–<1016 | 52 | 7690 | | | | 1.22 | 0.81–1.84 | Nd
| | | Q4 | Nd | 1016–<1357 | 41 | Nd | | | | 0.93 | 0.60–1.43 | nd
| | | Q5 | Nd | 1357- | 58 | 7690 | | | | 1.22 | 0.81– 1.82 | Nd
15800268 | Lin 2005 | Colorectal cancer (total Ca [mg]) | Q1 | Nd | <614 | 41 | 7691 | 10 y (120 mo) | Adj (second model) | RR (HR) | 1.0 | Ref | nd | 0.21
| | | Q2 | Nd | 614–<785 | 31 | Nd | | | | 0.74 | 0.46–1.18 | Nd
| | | Q3 | Nd | 785–<1016 | 52 | 7690 | | | | 1.19 | 0.78–1.81 | Nd
| | | Q4 | Nd | 1016–<1357 | 41 | Nd | | | | 0.92 | 0.58–1.44 | nd
| | | Q5 | Nd | 1357- | 58 | 7690 | | | | 1.20 | 0.79–1.85 | Nd
15800268 | Lin 2005 | Colorectal cancer (total Ca [mg]) | Q1 | Nd | <614 | 41 | Nd | 10 y (120 mo) | Adj (sensitivity analysis#) | RR (HR) | 1.0 | Ref | nd | 0.11
| | | Q2 | Nd | 614–<785 | 31 | Nd | | | | 0.74 | 0.45–1.21 | Nd
| | | Q3 | Nd | 785–<1016 | 52 | Nd | | | | 1.21 | 0.78–1.88 | Nd
| | | Q4 | Nd | 1016–<1357 | 41 | Nd | | | | 0.96 | 0.60–1.54 | nd
| | | Q5 | Nd | 1357- | 58 | nd | | | | 1.29 | 0.83–2.02 | Nd

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
15800268 | Lin 2005 | - first model used only age and RCT assignments (aspirin & Vit E) -second model used the full multivariate model - performed a sensitivity analysis by excluding cases developed colorectal cancer during the first year of follow-up and added symptomatic examination, and regular screening test of colorectal cancer [colono- or sigmoidoscopy] to the second model. - subgroup analyses (total fat intake [high vs. low], phosphorus intake [high vs. low], total fiber intake [high vs. low], total vitamin intake [high vs. low]) performed: all but high fat intake group (RR between Q1 and Q5 = 1.61 [0.87–2.98]; P for trend = 0.04) and low fiber intake (RR between Q1 and Q5 = 1.80 [1.50–3.23]; P=0.02) were NS (P for trend). - “proximal” colon cancer and “distal” colon cancer were reported as clinical outcome (P for trend=NS); not fully extracted.

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
15800268 | Lin 2005 | a) Eligibility criteria clear? (y/n) | N | a) Exposure assessor blinded to outcome info? (y/n) | nd | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories(eg quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders(other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
15800268 | Lin 2005 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories(eg quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders(other than age and sex)? ** (y/n) | Y | b) Loss to follow-up<20%? (y/n) | nd | b) Analysis was planned when cohort was formed? (y/n) | N
15800268 | Lin 2005 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Y | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | N | c)Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Poor reporting on inclusion/exclusion and actual selections, post-hoc analysis of an RCT of “cancer prevention” interventions: although adjusted; may have still been affected by these interventions; blinding not reported; power calculation not reported

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Lin 2007

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17533208 | Lin J2007 | Cohort study of enrolled in randomized trial | 39 876 women 45 years or older who were free of cancer and cardiovascular disease were enrolled in the WHS trial and completed a self-administered questionnaire at baseline about their medical history and lifestyle factors. During an average 10 years of follow-up, 276 premenopausal and 743 postmenopausal women had a confirmed diagnosis of incident invasive breast cancer and were included in the cohort. | 8389 who provided insufficient dietary information or had biologically uncertain or unknown menopause status. | During 1993 and 1995 | Women’s Health Study | Gov’t | GR

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
17533208 | Lin J 2007 | Cohort study of subjects enrolled in randomized trial | US 26°–61° | 31487 | 31487 | 55 y | 55–56 | 0% | nd | BMI = 26 | Current smokers = 8% to 20% Current users of postmenopausal hormone 56% to 72% | Current users of multivitamins, 15% to 76% Calcium supplement users, 6% to 90%

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
17533208 | Lin J 2007 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | No, Only correlation between vit D intake and plasma 25 OHD are available | nd | nd | Calculated from diet and multivitamin supplement
17533208 | Lin J2007 | Dietary calcium intake | Willet method | USDA Nutrient Database | Yes, as references to Nurses’ Health Study | | | | | Calcium dietary intake: Dairy products 53% pizza(4%), English muffin(3%), orange juice(2%), and bread(2%); other sources of vitamin D included dark fish (9%), tuna mix (5%), cereal(4%), and margarine(4%)

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17533208 | Lin J 2007 | Primary | Breast cancer | Incident cases of invasive breast cancer

UI | Author Year | Comments
17533208 | Lin J2007 | Vit D sources estimated from dietary questionnaire, no biomarker available. Thus excluded from the outcomes. Also available are subgroup analyses of relationships of calcium from dietary sources, supplements and breast cancer

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must be explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17533208 | Lin J2007 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes | multivitamin use and total energy intake in premenopausal and postmenopausal
17533208 | Lin J2007 | Demographics (e.g., age, gender, race, education)? | Yes | age at menopause and postmenopausal hormone therapy in postmenopausal women
17533208 | Lin J2007 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI
17533208 | Lin J2007 | Medical conditions | No
17533208 | Lin J2007 | Medication | Yes | hormone therapy in postmenopausal women
17533208 | Lin J2007 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | Yes | physical activity
17533208 | Lin J2007 | Smoking and other life styles variables | Yes | smoking status, alcohol consumption
17533208 | Lin J2007 | Other | Yes | family history of breast cancer in a first-degree relative, history of benign breast disease, age at menarche, parity, age at first birth

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca intake level | No. of Cases (Event) * | Total N ** | Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
17533208 | Lin J 2007 | Invasive breast cancer-Premenopausal | Total calcium intake Q1 | nd | <617 | 70 | ? unclear what was used in analyses Total followed up for 10 y = 10578 | Age, randomized treatment, BMI, family h/o breast cancer, h/o benign breast disease, etc | HR | 1 (Ref) | | | 0.14
| | | Total calcium intake Q2 | | 617 to <789 | 65 | ? 10578 | | HR | 0.78 | 0.52–1.17
| | | Total calcium intake Q3 | | 789 to <1026 | 44 | ? 10578 | | HR | 0.60 | 0.38–0.94
| | | Total calcium intake Q4 | | 1026 to<1366 | 59 | ? 10578 | | HR | 0.78 | 0.51–1.19
| | | Total calcium intake Q5 | | ≥1366 | 38 | ? 10578 | | HR | 0.64 | 0.40–1.03
| | Invasive breast cancer-Postmenopausal | Total calcium intake Q1 | | <617 | 104 | ?20909 | | HR | 1.0 (Ref) | | | 0.17
| | | Total calcium intake Q2 | | 617 to<789 | 116 | ?20909 | | HR | 1.12 | 0.85–1.47
| | | Total calcium intake Q3 | | 789 to<1026 | 112 | ?20909 | | HR | 1.10 | 0.83–1.44
| | | Total calcium intake Q4 | | 1026 to<1366 | 119 | ?20909 | | HR | 1.10 | 0.84–1.45
| | | Total calcium intake Q5 | | ≥1366 | 151 | ?20909 | | HR | 1.23 | 0.94–1.61

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
17533208 | Lin J 2007 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | N | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories(e.g. quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
17533208 | Lin J 2007 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | N | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories(e.g. quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up<20%? (y/n) | N | b) Analysis was planned when cohort was formed? (y/n) | N
17533208 | Lin J 2007 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Y | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | N | c) Justification of sample size (includes sample size calculations)? (y/n) | NA
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Lack of biomarker, reliance on dietary assessment alone, unclear about total N

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Lorenzen 2006

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
16400044 | Lorenzen 2006 | RCT | 12y ±6 mo old girls with Danish names; calcium intake either 1000–1304 mg/d or <713 mg/d | nd | nd | - | academic and industry | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
16400044 | Lorenzen 2006 | RCT | Frederiksberg, Copenhagen, Denmark 56 | 113 | 110 | 13.2 | nd | 0 | white | wt 51 Kg | nd | dietary calcium: 957 mg/d

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
16400044 | Lorenzen 2006 | 25(OH)D | | | | RIA | n | nd | nd | 25(OH)D: 34.5 mmol/L
| | Dietary calcium intake | FFQ (88 questions) | nd | n | | | | | dietary calcium: 957 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
16400044 | Lorenzen 2006 | calcium | calcium carbonate | 500 mg | 1 y | two 250 mg chewables with evening meal q day
| | placebo
Co-intervention(s) * :
Compliance/Adherence: | | | 80% in calcium; 82% in placebo

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
16400044 | Lorenzen 2006 | primary | body weight
| | | height
| | secondary | 25(OH)D

UI | Author Year | Comments
16400044 | Lorenzen 2006 | enrolled subject stratified by two groups depending on calcium intake: 1000–1304 mg/d or <713 mg/d

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
16400044 | Lorenzen 2006 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes | calcium intake
16400044 | Lorenzen 2006 | Demographics (e.g., age, gender, race, education)? | Yes | age
16400044 | Lorenzen 2006 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | weight, height, body fat
16400044 | Lorenzen 2006 | Medical conditions
16400044 | Lorenzen 2006 | Medication
16400044 | Lorenzen 2006 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | no
16400044 | Lorenzen 2006 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no
16400044 | Lorenzen 2006 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline/SE * | Final ** | Final SE * | Net difference | Net difference CI/SE/SD * | P between
16400044 | Lorenzen 2006 | weight Δ in medium (1000–1304 mg/d) calcium intake group | Kg | calcium | 1 y | 30 | 51.8 | 1.7 | 56.9 | 1.8 | | | NS
16400044 | Lorenzen 2006 | weight Δ in medium (1000–1304 mg/d) calcium intake group | Kg | placebo | 1 y | 30 | 50.7 | 1.6 | 55.6 | 1.6
| | weight Δ in low (<713 mg/d) calcium intake group | Kg | calcium | 1 y | 24 | 52.2 | 1.7 | 56.3 | 1.8 | | | NS
| | weight Δ in low (<713 mg/d) calcium intake group | Kg | placebo | 1 y | 26 | 49.5 | 1.7 | 52.5 | 1.6
| | height Δ in medium (1000–1304 mg/d) calcium intake group | cm | calcium | 1 y | 30 | 162.5 | 1.1 | 166.2 | 1.0 | | | NS
| | height Δ in medium (1000–1304 mg/d) calcium intake group | cm | placebo | 1 y | 30 | 161.9 | 1.2 | 165.9 | 1.1
| | height Δ in low (<713 mg/d) calcium intake group | cm | calcium | 1 y | 24 | 159.6 | 1.3 | 163.2 | 1.3 | | | NS
| | height Δ in low (<713 mg/d) calcium intake group | cm | placebo | 1 y | 26 | 160.1 | 1.5 | 163.2 | 1.4
| | 25(OH)D Δ in medium (1000–1304 mg/d) calcium intake group | mmol/L | calcium | 1 y | 29 | 37.5 | 2 | 35.1 | 3 | | | NS
| | 25(OH)D Δ in medium (1000–1304 mg/d) calcium intake group | mmol/L | placebo | 1 y | 29 | 39.2 | 3 | 32.2 | 2
| | 25(OH)D Δ in low (<713 mg/d) calcium intake group | mmol/L | calcium | 1 y | 24 | 30.8 | 2 | 25.7 | 3 | | | NS
| | 25(OH)D Δ in low (<713 mg/d) calcium intake group | mmol/L | placebo | 1 y | 24 | 29.2 | 2 | 28.5 | 3

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
16400044 | Lorenzen 2006 | RCT | nd | nd | NA | Y | Y | N | Y | Y | Y | B
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | relatively small sample size in each group; details of methods not completely reported; did not adjust for all potentially relevant confounders

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Lyons 2007

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17473911 | Lyons 2007 | RCT | All residents living in care homes across South Wales, including those with mobility, cognitive, visual, hearing or communication impairments | People already receiving ≥ 400 IU of vit D/d and those already have contradictions to vit D supplementation (not specified) | December 2000 and January 2003 | nd | The Wales Office of Research and Development for Health and Social Care | JHL

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City And Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
17473911 | Lyons 2007 | RCT | South Wales (51.96° N) | 3440 | 3343 | 84 (7.5) | 62–107 | 23.7% | nd | nd | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the Biomarker samples were drawn | Background exposure data
17473911 | Lyons 2007 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | 25(OH)D – DiaSorin radioimmunoassay | n | nd | nd | nd
17473911 | Lyons 2007 | Dietary calcium intake | nd | nd | nd | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
17473911 | Lyons 2007 | Vit D | Supplementation – ergo-calciferol | 822IU/d | 3 years | Every 4 months (Two 1.25 mg vit D tablets - 100,000 IU)
17473911 | Lyons 2007 | placebo | nd | nd | 3 years | Every 4 months
Co-intervention(s) * : | | | None
Compliance/Adherence: | | | 80% (percentage of occasions observed to take tablets)

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17473911 | Lyons 2007 | Primary | First fracture | Confirmed by matching every participant with computerized health records and searching through emergency department and in-patient records
17473911 | Lyons 2007 | Secondary | Fractures (hip/wrist/forearm/vertebrae) | Confirmed by matching every participant with computerized health records and searching through emergency department and in-patient records
17473911 | Lyons 2007 | Secondary | Mortality | nd

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17473911 | Lyons 2007 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
17473911 | Lyons 2007 | Demographics (e.g., age, gender, race, education)? | Yes-age, gender
17473911 | Lyons 2007 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no
17473911 | Lyons 2007 | Medical conditions
17473911 | Lyons 2007 | Medication
17473911 | Lyons 2007 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
17473911 | Lyons 2007 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no
17473911 | Lyons 2007 | Other | Residential home, nursing or dual-registered home, sheltered accommodation

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | Result | 95% CI | P btw
17473911 | Lyons 2007 | First fracture (all sites) | Vit D2 | median time to first fracture = 387 days (IQR: 220–582) | 205 | 1670 | HR vit d2/placebo | 0.95 | 0.79–1.15 | NS
17473911 | Lyons 2007 | First fracture (all sites) | Placebo | 367 days (IQR: 139–618) in the control group | 218 | 1673 | HR vit d2/placebo | 0.95 | 0.79–1.15 | NS
17473911 | Lyons 2007 | mortality | Vit D2 | 3 yr | 947 | 1670 | HR vit d2/placebo | 1.0 | 0.9–1.0 | NS
17473911 | Lyons 2007 | mortality | Placebo | 3 yr | 953 | 1673 | HR vit d2/placebo | 1.0 | 0.9–1.0 | NS

* Example: OR Ca/placebo

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
17473911 | Lyons 2007 | Fracture at the hip, wrist, forearm, and spine | HR, intervention to control – 1.00 (95% CI; 0.8–1.3)
17473911 | Lyons 2007 | Fracture at the hip | HR, intervention to control – 1.1 (95% CI; 0.8–1.1)

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
17473911 | Lyons 2007 | RCT-parallel | Y | Y | NA | Y | nd | Y | Y | Y | Y | B/C
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Poor reporting on the result section, no information on background diet. Quality rating C for mortality data due to inconsistent reporting between figure and table.

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Major 2007

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17209177 | Major 2007 | RCT | Women with low Ca intake (800 mg Ca/d), premenopausal, stable weight, overweight or obese (BMI 27–40), limited exercise (<3 periods of 20 min per week), general good health, BP<160/95 | Ca supplementation Menopause Smoking Cholesterol level requiring treatment Abnormal thyroid function Medication that could affect weight Consumption of >5 cups coffee/day Pregnant or breastfeeding | nd | none | Wyeth, professional organization (CVD, DM), Gov’t | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
17209177 | Major 2007 | RCT | Quebec City, QC, Canada 47° | 84 | 63 | 43 (~5.5) | nd (premenopausal) | 0 | nd | BMI – 31.9 (~3) | Healthy, overweight/obese | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | None
17209177 | Major 2007 | Dietary calcium intake | 3 d dietary record (Tremblay 1983) | Canadian Nutrient File | No | | | | | Ca+D: 708.0 (119) mg/d Placebo: 700.5 (99) mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
17209177 | Major 2007 | Vit D + Ca | Supplements (Caltrate 600+D) | Ca: 1200 mg (Ca carbonate per website) Vit D 400 IU (cholecalciferol per website) | 15 wk | 1 capsule 2x/d
| | Placebo | nd
Co-intervention(s) * : | | | Energy restriction diet: −700 Kcal/d, maintaining “diet quality”
Compliance/Adherence: | | | nd

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17209177 | Major 2007 | 2° | Weight | Kg
| | 2° | BMI
| | 2° | SBP
| | 2° | DBP

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17209177 | Major 2007 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | No
17209177 | Major 2007 | Demographics (e.g., age, gender, race, education)? | No
17209177 | Major 2007 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No
17209177 | Major 2007 | Medical conditions | No
17209177 | Major 2007 | Medication | No
17209177 | Major 2007 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | No
17209177 | Major 2007 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | No
17209177 | Major 2007 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline SD * | Final or Change | Final or Change SD * | Net difference | Net difference CI/SE/SD * | P between
17209177 | Major 2007 | Weight | Kg | Ca + D | 15 wk | 30 | 81.5 | 8.3 | 77.5 | 9.0 | −1.0 | | 0.19
17209177 | Major 2007 | Weight | Kg | Placebo | | 33 | 83.6 | 11.1 | 80.6 | 11.7
| | BMI | Kg/m ^ 2 ^ | Ca + D | 15 wk | 30 | 31.4 | 2.5 | 29.8 | 2.8 | −0.4 | | 0.23
| | BMI | Kg/m ^ 2 ^ | Placebo | | 33 | 32.3 | 3.54 | 31.1 | 3.7
| | SBP | mmHg | Ca + D | 15 wk | 30 | 112.4 | 10.8 | −4.1 | 6.8 | −2.5 | | 0.18
| | SBP | mmHg | Placebo | | 33 | 109.5 | 8.5 | −1.6 | 7.6
| | DBP | mmHg | Ca + D | 15 wk | 30 | 74.9 | 8.9 | −3.0 | 4.9 | 0 | | 1.0
| | DBP | mmHg | Placebo | | 33 | 75.2 | 7.0 | −3.0 | 5.9

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “− “ sign: e.g. +2.8 or −2.8

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
17209177 | Major 2007 | RCT | nd | nd | NA | N | Y | N | Technically OK, but poor choice (ANOVA) | N | Y | C
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Design methods poorly described. High dropout due to problems with diet/exercise compliance etc. These people were fully dropped. Questionable choice of statistical analysis.

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Mallet 1986

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
3755517 | Mallet 1986 | RCT | term pregnancy, white, lived in same town | nd | nd | nd | nd | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
3755517 | Mallet 1986 | RCT | NW France, 48º N | 77 | 77 | 25 | 18–36 | 0 | white | nd | nd | Ca intake 550 to 1000 mg/d in 55% of the subjects

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed information as possible on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
3755517 | Mallet 1986 | 25(OH)D | | | | Competitive protein binding assay | y; reproducibility at 20 nmol/L 6% | nd | winter, Feb/Mar | 45% were outside <1 h/d
| | Dietary calcium intake

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
3755517 | Mallet 1986 | unsupplemented
| | vit D 1000 IU/d | | 1000 IU | daily for last 3 mo pregnancy | nd
| | vit D 200,000 IU 1x | | | !x at 7 mo pregnancy
Co-intervention(s) * :
Compliance/Adherence: | | | nd

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
3755517 | Mallet 1986 | primary | maternal 25(OH)D at term
| | | cord blood 25(OH)D at term
| | primary | maternal 1,25 (OH)2D at term
| | | cord blood 1,25 (OH02D at term
| | secondary | birth weight

UI | Author Year | Comments
3755517 | Mallet 1986 | unsupplemented group was not randomized

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
3755517 | Mallet 1986 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
3755517 | Mallet 1986 | Demographics (e.g., age, gender, race, education)? | Yes * | age, race
3755517 | Mallet 1986 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no *
3755517 | Mallet 1986 | Medical conditions
3755517 | Mallet 1986 | Medication
3755517 | Mallet 1986 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | yes | spent time outside
3755517 | Mallet 1986 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no *
3755517 | Mallet 1986 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥ 2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure Category/Intervention Group | Crude or Adjusted analysis? | Mean Follow-up (months) | No. Analyzed | Baseline | Baseline CI/SE/SD * | Final ** | Final SD * | Net difference *** | Net difference CI/SE/SD * | P between groups ***
3755517 | Mallet 1986 | maternal 25(OH)D at term | nmol/L | unsupplemented | crude | 3 mo | 29 | nd | nd | 9.4 | 4.9
| | | | 1000 IU/d | | | 21 | nd | nd | 25.3 | 7.7
| | | | 200,000 IU | | | 27 | nd | nd | 26 | 6.4
| | cord 25(OH)D | nmol/L | unsupplemented | crude | 3 mo | 29 | nd | nd | 5.3 | 2.5
| | | | 1000 IU/d | | | 21 | nd | nd | 15.7 | 5.1
| | | | 200,000 IU | | | 27 | nd | nd | 18.2 | 5.2
| | birth weight | g | unsupplemented | crude | | nd | nd | nd | 3460 | 70 | | | NS
| | | | 1000 IU/d | | | nd | nd | nd | 3370 | 80
| | | | 200,000 IU | | | nd | nd | nd | 3210 | 90
| | maternal 1,25(OH)2D at term | pmol/L | unsupplemented | crude | 3 mo | 29 | nd | nd | 66.1 | 14
| | | | 1000 IU/d | | | 21 | nd | nd | 49.9 | 16
| | | | 200,000 IU | | | 27 | nd | nd | 69 | 22
| | cord 1,25(OH)2D at term | pmol/L | unsupplemented | crude | 3 mo | 29 | nd | nd | 47 | 16
| | | | 1000 IU/d | | | 21 | nd | nd | 42.6 | 12
| | | | 200,000 IU | | | 27 | nd | nd | 46.1 | 15

Duplicate one row per exposure category or intervention group. Please write “nd” if there was no data reported. DO NOT LEAVE BLANK.

* Please choose one and delete the others

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
3755517 | Mallet 1986 | curve4 data rejected due to nonRCT design when comparing to the unsupplemented group

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
3755517 | Mallet 1986 | RCT | n | n | NA | nd | nd | nd | y | n | n | C
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | small sample size; incomplete data on infants

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT– Parallel, RCT– Cross-over, RCT– Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse events.

## Margolis 2008

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
18824662 | Margolis 2008 | RCT | Women aged 50 to 79 years | Women with < 3years of predicted survival, a history of kidney stone or hypercalcemia, current oral corticosteroid use or current calcitriol use | 1993–1998 | WHI | NIH | JHL

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
18824662 | Margolis 2008 | RCT | US | 36282 | 36282 | 62 (7) | 50–79 | 0% | 83% White, 9% Black, 4% Hispanic, <1% American Indian, 2% Asian/Pacific Islander | BMI <25 28.0% BMI 25 to <30 35.4% BMI ≥30 36.6% | healthy | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed information as possible on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
18824662 | Margolis 2008 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | Diasorin Liaison chemiluminescent immunoassay | nd | nd | nd | 25(OH)D nmol/L <34.4 25.0%, 34.4–47.6 25.2%, 47.7–64.6 24.9%, ≥ 64.7 24.8%
18824662 | Margolis 2008 | Dietary calcium intake | Food frequency questionnaire | nd | nd | nd | nd | | nd | Total Ca intake mg/d <600 19.7%, 600–799 14.4%, 800–1199 26.3%, ≥1200 39.6%

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
18824662 | Margolis 2008 | Ca+VitD | Ca-Tablet as calcium carbonate VitD-provided by GlaxoSmithKline | Ca 1000mg VitD3 400IU | 7y | 2 times/d
18824662 | Margolis 2008 | Placebo | nd
Co-intervention(s) * : | | | None
Compliance/Adherence: | | | 60% (proportion taking ≥ study medication, adherence assessed by weighing returned bottles)

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
18824662 | Margolis 2008 | primary | Hypertension | Self-report of medication prescribed for hypertension or any BP ≥ 140/90 mm Hg

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
18824662 | Margolis 2008 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | | Ca intake, VitD intake, sodium intake,
18824662 | Margolis 2008 | Demographics (e.g., age, gender, race, education)? | Yes * | Age, race, education,
18824662 | Margolis 2008 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes * | BMI
18824662 | Margolis 2008 | Medical conditions | | Blood pressure, hypertensive status
18824662 | Margolis 2008 | Medication
18824662 | Margolis 2008 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
18824662 | Margolis 2008 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes * | Physical activity, smoking, alcohol intake,
18824662 | Margolis 2008 | Other | | 25(OH)vitD

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | Result | 95% CI | P btw
18824662 | Margolis 2008 | Hypertension | CaD | 74 mo | 3377 | 8597 | HR | | | | 1.01 | 0.96, to 1.06 | 0.69
18824662 | Margolis 2008 | Hypertension | Placebo | 74 mo | 3315 | 8525 | HR | | | | 1.01 | 0.96, to 1.06 | 0.69

* Example: OR Ca/placebo

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline CI/SE/SD * | Final or Delta ** | Final or Delta CI/SE/SD * | Net difference | Net difference CI/SE/SD * | P between
18824662 | Margolis 2008 | Systolic BP | mmHg | CaD | 74 mo | | | | | | +0.22 | −0.05 to 0.49 | 0.11
18824662 | Margolis 2008 | Systolic BP | mmHg | Placebo | 74 mo
18824662 | Margolis 2008 | Diastolic BP | mmHg | CaD | 74 mo | | | | | | +0.11 | −0.04 to 0.27 | 0.14
18824662 | Margolis 2008 | Diastolic BP | mmHg | Placebo | 74 mo

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
18824662 | Margolis 2008 | In the subsample of subjects with measured 25(OH)vitD, those with lower levels had a higher risk of incident hypertension. Test if interaction between Ca/vitD treatment assignment and 25(OH)vitD on hypertension risk (p-value <.01)

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
18824662 | Margolis 2008 | RCT- parallel | nd | nd | n | y | n | y | y | y | y | C
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Open-label use of Ca and vitD supplements as long as non-study use of vitD did not exceed 600IU daily. UL was raised to 1000IU after IOM report release, outcome measure - Self-report of medication prescribed for hypertension

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT– Parallel, RCT– Cross-over, RCT– Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse events.

## Marniemi 2005

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
15955467 | Marniemi 2005 | Cohort study | 65–99 in 1986–87. Around Turku, Finland. | Men<75 in NH Women<70 in NH Missing lab data Obvious inaccuracies in dietary data | 1986–87 | (Turku, Finland) | nd | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
15955467 | Marniemi 2005 | Cohort study | Turku, Finland 60° | 769 | 755 | 79 (nd) | 65–99 | 48% | White 100% (probably) | nd | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
15955467 | Marniemi 2005 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | RIA (Incstar) | No | Frozen. Unclear.≤10 y | nd | nd
15955467 | Marniemi 2005 | Dietary calcium intake | Interview (nd) | Nutrica database at the Social Insurance Institution (Knuts 1987; Hakala 1996) | No | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
15955467 | Marniemi 2005 | 1° | AMI | ICD 9 codes from national death registry and national hospital discharge registry
| | | Stroke | Same

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
15955467 | Marniemi 2005 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes (Ca analyses) | Weight adjusted intake of total energy (Ca analyses)
15955467 | Marniemi 2005 | Demographics (e.g., age, gender, race, education)? | Yes | Age, sex
15955467 | Marniemi 2005 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No
15955467 | Marniemi 2005 | Medical conditions | No
15955467 | Marniemi 2005 | Medication | No
15955467 | Marniemi 2005 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | No
15955467 | Marniemi 2005 | Smoking and other life styles variables | Yes | Smoking
15955467 | Marniemi 2005 | Other | Yes | “Functional capacity” (Vit D analyses) TC, HDL, SBP

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Followup, mean | Mean Ca intake | No. of Cases (Event) * | No. of Non- cases/Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
15955467 | Marniemi 2005 | AMI | Calcium intake, Tertile 1 | 10 y | nd | nd | ~252 | Adjusted | RR | 1 | Ref | | nd
| | | Tertile 2 | | nd | nd | ~252 | | | 0.866 | 0.57, 1.37
| | | Tertile 3 | | nd | nd | ~252 | | | 1.14 | 0.70, 1.84
| | AMI | 25(OH)D level, Tertile 1 | 10 y | nd | nd | ~252 | Adjusted | RR | 1 | Ref | | nd
| | | Tertile 2 | | nd | nd | ~252 | | | 0.987 | 0.64, 1.53
| | | Tertile 3 | | nd | nd | ~252 | | | 0.769 | 0.47, 1.27
| | AMI | 1.25(OH) _ 2 _ D level, Tertile 1 | 10 y | nd | nd | ~252 | Adjusted | RR | 1 | Ref | | nd
| | | Tertile 2 | | nd | nd | ~252 | | | 1.05 | 0.68, 1.62
| | | Tertile 3 | | nd | nd | ~252 | | | 0.821 | 0.52, 1.30
| | Stroke | Calcium intake, Tertile 1 | 10 y | nd | nd | ~252 | Adjusted | RR | 1 | Ref | | nd
| | | Tertile 2 | | nd | nd | ~252 | | | 0.981 | 0.53, 1.81
| | | Tertile 3 | | nd | nd | ~252 | | | 1.34 | 0.70, 2.55
| | Stroke | 25(OH)D level, Tertile 1 | 10 y | nd | nd | ~252 | Adjusted | RR | 1 | Ref | | nd
| | | Tertile 2 | | nd | nd | ~252 | | | 1.13 | 0.62, 2.05
| | | Tertile 3 | | nd | nd | ~252 | | | 0.999 | 0.51, 1.94
| | Stroke | 1.25(OH) _ 2 _ D level, Tertile 1 | 10 y | nd | nd | ~252 | Adjusted | RR | 1 | Ref | | nd
| | | Tertile 2 | | nd | nd | ~252 | | | 0.631 | 0.37, 1.09
| | | Tertile 3 | | nd | nd | ~252 | | | 0.406 | 0.22, 0.77 | 0.005

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
15955467 | Marniemi 2005 | No data on ranges, medians, etc. of intake or level tertiles.

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers | | Comparator | | Statistical Analysis | | Outcome | | Design
15955467 | Marniemi 2005 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | Y | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | Y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | N | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
| | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | Y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | N | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
| | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | C (or NA)
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | No intake values or level values provided for tertiles. Data not reported.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Martinez 2002

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
12020102 | Martinez 2002 | Cohort study Participants are included in an RCT | Men and women 40–80 years of age who had undergone removal of one or more colorectal adenoma(s) 3 mm or larger at colonoscopy within three months prior to study entry were recruited from the Phoenix, Arizona, metropolitan area | Individuals with a personal history of inflammatory bowel disease or hereditary colon cancer syndromes. | nd | Wheat Bran Fiber (WBF) trial | NCI | AT

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake...etc.)
12020102 | Martinez 2002 | Cohort study | Phoenix, Arizona, metropolitan area (33° 29′ N) | 1429 | 1304 | According to calcium intake, 1 ^ st ^ quartile:64.3 (9.3); 2 ^ nd ^ quartile: 66.4 (8.5); 3 ^ rd ^ quartile: 66.5 (8.9); 4 ^ th ^ quartile:66.2 (8.4) | nd | 57.1 | nd | nd | Regular aspirin use in the past 10 years: 28.2% Previous polyps: 39.2% Family CRC history: 16.9% Current smoking: 13.7% According to calcium intake, Alcohol (g), 1 ^ st ^ quartile: 10.9 (22.4); 2 ^ nd ^ quartile: 7.5 (13.2); 3 ^ rd ^ quartile: 6.5 (11); 4 ^ th ^ quartile: 3.9 (8.2) | According to calcium intake Energy (kcal), 1 ^ st ^ quartile:1809 (655); 2 ^ nd ^ quartile: 2038 (683); 3 ^ rd ^ quartile: 1986 (689); 4 ^ th ^ quartile:1866 (742) Total fat (g), 1 ^ st ^ quartile: 70.9 (13.7); 2 ^ nd ^ quartile: 69.9 (12); 3 ^ rd ^ quartile: 68.4 (13.1); 4 ^ th ^ quartile: 66.7 (13.5)

UI | Author Year | Study Design* | Location (e.g., City and Country, latitude) | N enrolled*** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
12020102 | Martinez 2002 | Cohort study | Phoenix, Arizona, metropolitan area | 1429 | 1304 | According to calcium intake, 1 ^ st ^ quartile:64.3 (9.3); 2 ^ nd ^ quartile: 66.4 (8.5); 3 ^ rd ^ quartile: 66.5 (8.9); 4 ^ th ^ quartile:66.2 (8.4) | nd | 57.1 | nd | nd | Regular aspirin use in the past 10 years: 28.2% Previous polyps: 39.2 Family CRC history: 16.9 Current smoking: 13.7 According to calcium intake, Alcohol (g), 1 ^ st ^ quartile: 10.9 (22.4); 2 ^ nd ^ quartile: 7.5 (13.2); 3 ^ rd ^ quartile: 6.5 (11); 4 ^ th ^ quartile: 3.9 (8.2) | According to calcium intake Dietary fiber (g), 1 ^ st ^ quartile: 20 (5.9); 2 ^ nd ^ quartile: 22.2 (6.8); 3 ^ rd ^ quartile: 22.8 (7.5); 4 ^ th ^ quartile: 23.4 (7.1) Red meat (g), 1 ^ st ^ quartile: 72.5 (56.9); 2 ^ nd ^ quartile: 65.8 (47.7); 3 ^ rd ^ quartile: 61.1 (46.9); 4 ^ th ^ quartile: 50.6 (40.2)

UI | Author Year | Study Design* | Location (e.g., City and Country, latitude) | N enrolled*** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
12020102 | Martinez 2002 | Cohort study | Phoenix, Arizona, metropolitan area (33° 29′ N) | 1429 | 1304 | According to calcium intake, 1 ^ st ^ quartile: 64.3 (9.3); 2 ^ nd ^ quartile: 66.4 (8.5); 3 ^ rd ^ quartile: 66.5 (8.9); 4 ^ th ^ quartile:66.2 (8.4) | nd | 57.1 | nd | nd | Regular aspirin use in the past 10 years: 28.2% Previous polyps: 39.2 Family CRC history: 16.9 Current smoking: 13.7 According to calcium intake, Alcohol (g), 1 ^ st ^ quartile: 10.9 (22.4); 2 ^ nd ^ quartile: 7.5 (13.2); 3 ^ rd ^ quartile: 6.5 (11); 4 ^ th ^ quartile: 3.9 (8.2) | According to calcium intake Supplemental calcium (mg), 1 ^ st ^ quartile: 11.6(35.6); 2 ^ nd ^ quartile: 34.6(72.1); 3 ^ rd ^ quartile: 92.2(170.7); 4 ^ th ^ quartile: 582.8(516) Supplemental vitamin D (IU), 1 ^ st ^ quartile: 65.4(151.8); 2 ^ nd ^ quartile: 115.7(189.3); 3 ^ rd ^ quartile: 163.7(256.2); 4 ^ th ^ quartile: 227.5(248.2) Median total calcium intake(mg/day), 1 ^ st ^ quartile: 629; 2 ^ nd ^ quartile: 874; 3 ^ rd ^ quartile: 1107; 4 ^ th ^ quartile: 1638

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
12020102 | Martinez 2002 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | na | na | na | na | na
12020102 | Martinez 2002 | Dietary calcium intake | 113-item Arizona Food Frequency Questionnaire (AFFQ) | United States Department of Agriculture’s Continuing Survey of Food Intake of Individuals, 1996 and the United States Department of Agriculture’s Nutrient Database for Standard Reference, Version 13 | y assessment of its validity and reliability [recurrence. Cancer Epidemiol Biomarkers Prev 8: 941–946] have been previously reported | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
12020102 | Martinez 2002 | primary | Adenoma recurrence | One or more adenomas or colorectal cancer detected by colonoscopy any time after randomization

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
12020102 | Martinez 2002 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Dietary fiber; total vitamin D; energy intake
12020102 | Martinez 2002 | Demographics (e.g., age, gender, race, education)? | Yes (age; gender)
12020102 | Martinez 2002 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No
12020102 | Martinez 2002 | Medical conditions | Self reported history of polyps prior to baseline; adenoma number (≥ 3 vs. < 3); adenoma location (any proximal vs. non-proximal)
12020102 | Martinez 2002 | Medication | Regular use of aspirin in the previous 10 years
12020102 | Martinez 2002 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | No
12020102 | Martinez 2002 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | No
12020102 | Martinez 2002 | Other | Number of colonoscopies after baseline

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

Covariates: age, gender

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non-cases N ** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups *** | P for trend ****
12020102 | Martinez 2002 | Adenoma recurrence | 1 ^ st ^ total calcium intake quartile (mg/day) | | < 778 | 178 | 148 | 36.8 | adjusted | OR | 1.00 | | | 0.002
| | Adenoma recurrence | 2 ^ nd ^ total calcium intake quartile (mg/day) | | 778–996 | 175 | 151 | 36.8 | adjusted | OR | 0.90 | 0.66–1.23 | nd | 0.002
| | Adenoma recurrence | 3 ^ rd ^ total calcium intake quartile (mg/day) | | 997–1279 | 148 | 178 | 36.8 | adjusted | OR | 0.64 | 0.47–0.88 | nd | 0.002
| | Adenoma recurrence | 4 ^ th ^ total calcium intake quartile(mg/day) | | >1279 | 138 | 188 | 36.8 | adjusted | OR | 0.65 | 0.47–0.90 | nd | 0.002

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

Covariates: age, gender, number of colonoscopies, history of polyps prior to baseline, aspirin use, dietary fiber, and total vitamin D intake

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | No. of Non-cases N** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI** | P between groups*** | P for trend****
12020102 | Martinez 2002 | Adenoma recurrence | 1 ^ st ^ total calcium intake quartile (mg/day) | | < 778 | 178 | 148 | 36.8 | adjusted | OR | 1.00 | | | 0.004
| | Adenoma recurrence | 2 ^ nd ^ total calcium intake quartile (mg/day) | | 778–996 | 175 | 151 | 36.8 | adjusted | OR | 0.92 | 0.65, 1.29 | nd | 0.004
| | Adenoma recurrence | 3 ^ rd ^ total calcium intake quartile (mg/day) | | 997–1279 | 148 | 178 | 36.8 | adjusted | OR | 0.66 | 0.47, 0.94 | nd | 0.004
| | Adenoma recurrence | 4 ^ th ^ total calcium intake quartile (mg/day) | | >1279 | 138 | 188 | 36.8 | adjusted | OR | 0.62 | 0.42, 0.90 | nd | 0.004

Covariates: age, gender, number of colonoscopies, history of polyps prior to baseline, aspirin use, dietary fiber, and total vitamin D intake, location and number of polyps at baseline

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | No. of Non-cases N** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI** | P between groups*** | P for trend****
12020102 | Martinez 2002 | Adenoma recurrence | 1 ^ st ^ total calcium intake quartile (mg/day) | | < 778 | 178 | 148 | 36.8 | adjusted | OR | 1.00 | | | 0.005
| | Adenoma recurrence | 2 ^ nd ^ total calcium intake quartile (mg/day) | | 778–996 | 175 | 151 | 36.8 | adjusted | OR | 0.94 | 0.66, 1.32 | nd | 0.005
| | Adenoma recurrence | 3 ^ rd ^ total calcium intake quartile (mg/day) | | 997–1279 | 148 | 178 | 36.8 | adjusted | OR | 0.68 | 0.48, 0.97 | nd | 0.005
| | Adenoma recurrence | 4 ^ th ^ total calcium intake quartile (mg/day) | | >1279 | 138 | 188 | 36.8 | adjusted | OR | 0.62 | 0.42, 0.90 | nd | 0.005

Male patients

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | No. of Non-cases/Total N** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI** | P between groups*** | P for trend****
12020102 | Martinez 2002 | Adenoma recurrence | 1 ^ st ^ total calcium intake quartile (mg/day) | | < 778 | nd | nd | 36.8 | adjusted | OR | 1.00 | | | nd
| | Adenoma recurrence | 2 ^ nd ^ total calcium intake quartile (mg/day) | | 778–996 | nd | nd | 36.8 | adjusted | OR | 1.01 | 0.68–1.51 | nd | nd
| | Adenoma recurrence | 3 ^ rd ^ total calcium intake quartile (mg/day) | | 997–1279 | nd | nd | 36.8 | adjusted | OR | 0.83 | 0.54–1.26 | nd | nd
| | Adenoma recurrence | 4 ^ th ^ total calcium intake quartile (mg/day) | | >1279 | nd | nd | 36.8 | adjusted | OR | 0.67 | 0.40–1.10 | nd | nd

Female patients

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | No. of Non-cases/Total N** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI** | P between groups*** | P for trend****
12020102 | Martinez 2002 | Adenoma recurrence | 1 ^ st ^ total calcium intake quartile (mg/day) | | < 778 | nd | nd | 36.8 | adjusted | OR | 1.00 | | | nd
| | Adenoma recurrence | 2 ^ nd ^ total calcium intake quartile (mg/day) | | 778–996 | nd | nd | 36.8 | adjusted | OR | 0.81 | 0.40–1.64 | nd | nd
| | Adenoma recurrence | 3 ^ rd ^ total calcium intake quartile (mg/day) | | 997–1279 | nd | nd | 36.8 | adjusted | OR | 0.42 | 0.21–1.87 | nd | nd
| | Adenoma recurrence | 4 ^ th ^ total calcium intake quartile (mg/day) | | >1279 | nd | nd | 36.8 | adjusted | OR | 0.52 | 0.28–0.98 | nd | nd

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
12020102 | Martinez 2002 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | N | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories(eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
12020102 | Martinez 2002 | b) Sampling of population random or consecutive? (y/n) | N | b) Outcome assessor blinded to exposure measurement? (y/n) | N | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories(eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
12020102 | Martinez 2002 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Y | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Study was not design to evaluate calcium intake and adenoma recurrence; assessor blinding not reported; power calculation not reported

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Marya 1981

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
7239350 | Marya 1981 | Other intervention study | pregnancy | preeclampsia, antepartum hemorrhage, twins | nd | - | nd | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
7239350 | Marya 1981 | Other intervention study | Rohtak, India 28° 54′ N | 70 | 70 | nd | nd | 0 | Indian | nd | nd | daily milk <500 mL; vit D (diet) <30 IU/d

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
7239350 | Marya 1981 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | | | | | vit D (diet) <30 IU/d
| | Dietary calcium intake

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specified)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., bran name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
7239350 | Marya 1981 | | | 1200 IU vit D + 375 mg Calcium | qd through 3 ^ rd ^ trimester
| | | | 600,000 U vit D2 once in 7 ^ th ^ and 8 ^ th ^ month pregnancy
Co-intervention(s) * :
Compliance/Adherence:

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
7239350 | Marya 1981 | secondary | birth weight | -

UI | Author Year | Comments
7239350 | Marya 1981 | two supplement groups were randomly selected; control group was not

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
7239350 | Marya 1981 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
7239350 | Marya 1981 | Demographics (e.g., age, gender, race, education)? | no
7239350 | Marya 1981 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no
7239350 | Marya 1981 | Medical conditions
7239350 | Marya 1981 | Medication
7239350 | Marya 1981 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
7239350 | Marya 1981 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no
7239350 | Marya 1981 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline CI/SE/SD * | Final or Delta ** | Final or Delta CI/SE/SD * | Net difference | Net difference CI/SE/SD * | P between
7239350 | Marya 1981 | birth weight | | 1200 IU/d vit D + calcium (3 ^ rd ^ trimester) | | 25 | | | 2.89 | 0.32 | | | 0.05
7239350 | Marya 1981 | birth weight | | control | | 75 | | | 2.73 | 0.36
| | | | 1.2 mil IU vit D total | | 20 | | | 3.14 | 0.45 | | | 0.001
| | | | control | | 75 | | | 2.73 | 0.36

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
7239350 | Marya 1981 | quasi-RCT | nd | N | NA | Y | N | N | N | N | N | C
Adverse Event(s): ** | | | | | | no information provided
Explanation for Overall Quality Grade (if not Grade A): | | | | | | small sample size, no comparative data between the two supplemented groups; study methodology not completely reported

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Marya 1987

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
3623260 | Marya 1987 | RCT | pregnancy | nd | nd | - | nd | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
3623260 | Marya 1987 | RCT | Rohtak, India 28° 54′ N | 400 | 400 | nd | 20–35 | 0 | Indian | nd | nd | diet: calcium 500 mg/d and vit D 40 IU/d

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | | | | diet: vit D 40 IU/d
3623260 | Marya 1987 | Dietary calcium intake | nd | nd | n | | | | | diet: calcium 500 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
3623260 | Marya 1987 | vit D and Ca | nd | calcium 375 mg and Vit D 1200 IU from 20–24 wk onwards | ≤16–20 wk | nd
| | placebo
Co-intervention(s) * :
Compliance/Adherence: | | | nd

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
3623260 | Marya 1987 | primary | toxemia | nd

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
3623260 | Marya 1987 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
3623260 | Marya 1987 | Demographics (e.g., age, gender, race, education)? | no
3623260 | Marya 1987 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no
3623260 | Marya 1987 | Medical conditions
3623260 | Marya 1987 | Medication
3623260 | Marya 1987 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
3623260 | Marya 1987 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no
3623260 | Marya 1987 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | Result | 95% CI | P btw
3623260 | Marya 1987 | toxemia | ca+ vit D suppl | pregnancy | 12 | 200 | | 6% vs. 9% | | >0.05 per chi2
3623260 | Marya 1987 | toxemia | no suppl | pregnancy | 18 | 200 | | 6% vs. 9% | | >0.05 per chi2

* Example: OR Ca/placebo

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
3623260 | Marya 1987 | RCT | nd | N | NA | Y | N | N | N | N | N | C
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | study methodology not completely reported

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Marya 1988

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
3243609 | Marya 1988 | RCT | pregnancy | preeclampsia, antepartum hemorrhage, preterm delivery, twin pregnancies | nd | - | nd | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
3243609 | Marya 1988 | RCT | Rohtak, India 28° 54′ N | 200 | 200 | 24 | 22–35 | 0 | Indian | weight 54 Kg | nd | Vit D 35 IU/d; calcium 429 mg/d (diet?)

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
3243609 | Marya 1988 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | | | | vit D 35 IU/d (diet?)
| | Dietary calcium intake | nd | nd | | | | | | calcium 429 mg/d (diet?)

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
3243609 | Marya 1988 | vit D | unclear if this is oral or parenteral supplementation | 600,000 IU once each in 7 ^ th ^ and 8 ^ th ^ month pregnancy
| | placebo
Co-intervention(s) * :
Compliance/Adherence:

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
3243609 | Marya 1988 | primary | newborn birth weight
| | secondary | crown-heel length

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
3243609 | Marya 1988 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
3243609 | Marya 1988 | Demographics (e.g., age, gender, race, education)? | no
3243609 | Marya 1988 | Anthropometrics (e.g., BMI, body weight, % body fat)? | yes | weight gain in 3 ^ rd ^ trimester
3243609 | Marya 1988 | Medical conditions
3243609 | Marya 1988 | Medication
3243609 | Marya 1988 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
3243609 | Marya 1988 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no
3243609 | Marya 1988 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | Result | 95% CI | P btw
3243609 | Marya 1988 | birth weight <2.5 Kg | 1.2 million IU vit D | | | | | 4% vs. 19%
3243609 | Marya 1988 | birth weight <2.5 Kg | no supplement | | | | | 4% vs. 19%

* Example: OR Ca/placebo

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline CI/SE/SD * | Final or Delta ** | Final or Delta CI/SE/SD * | Net difference | Net difference CI/SE/SD * | P between
3243609 | Marya 1988 | newborn birth weight | Kg | 1.2 million IU vit D | | 100 | | | 2.99 | 0.36 | | | <0.05
3243609 | Marya 1988 | newborn birth weight | Kg | no supplement | | 100 | | | 2.80 | 0.37
| | gestational age | wk | 1.2 million IU vit D | | 100 | | | 38.65 | 1.77 | | | >0.05
| | gestational age | wk | no supplement | | 100 | | | 38.86 | 1.69
| | crown-heel length | cm | 1.2 million IU vit D | | 100 | | | 50.06 | 1.79 | | | <0.001
| | crown-heel length | cm | no supplement | | 100 | | | 48.45 | 2.04

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

Subgroup in women with similar weight gain 3 ^ rd ^ trimester

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline CI/SE/SD* | Final or Delta** | Final or Delta CI/SE/SD* | Net difference | Net difference CI/SE/SD* | P between
3243609 | Marya 1988 | newborn birth weight in women with similar weight gain (50–55 g/d) in 3 ^ rd ^ trimester | | 1.2 million IU vit D | | 33 women | | | 2.95 | 0.17 | | | <0.01
3243609 | Marya 1988 | newborn birth weight in women with similar weight gain (50–55 g/d) in 3 ^ rd ^ trimester | | no supplement | | 25 women | | | 2.76 | 0.25

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
3243609 | Marya 1988 | RCT | nd | N | NA | Y | N | N | Y | Y | N | C
Adverse Event(s): ** | | | | | | no information provided
Explanation for Overall Quality Grade (if not Grade A): | | | | | | study methodology not completely reported

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Mastaglia 2006

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
16391587 | Mastaglia 2006 | RCT | 50–70 y women; menopause ≥1 y; BMD T- score < −1 | vit D or meds that affect mineral metabolism within past 12 mo; kidney stone, tumors, liver or kidney disease; hypercalciuria | winter, spring 2002 | - | non-profit and industry | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
16391587 | Mastaglia 2006 | RCT | Buenos Aires, Argentina (34°S) | 45 | 45 | 65 (median, est.) | 54.5–77 (IQR, est.) | 0 | nd | BMI 27.4 (median, est.) | BMD T- score < −1 | 25(OH)D level 42 nmol/L (median, est.)

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
16391587 | Mastaglia 2006 | 25(OH)D | | | | RIA (DIASORIN) | y; interassay and intraassay CV 19%, 17.6% | nd | winter, spring | 25(OH)D level 42 nmol/L (median, est.)
| | Dietary calcium intake | nd | nd | | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
16391587 | Mastaglia 2006 | calcium 500 mg/d + No vit D | calcium carbonate | calcium 500 mg/d + No vit D | 3 mo | 1 tablet qd
| | calcium 500 mg/d + vit D 125 μg/d | calcium carbonate + vit D2 (Spedrog-Caillon, Argentina) | calcium 500 mg/d + 5000 IU/d vit D2 | 3 mo | 2 drop qd of vit D2 + 1 tablet of calcium qd
| | calcium 500 mg/d + vit D 250 μg/d | calcium carbonate + vit D2 (Spedrog-Caillon, Argentina) | calcium 500 mg/d + 10000 IU/d vit D2 | 3 mo | 4 drop qd of vit D2 + 1 tablet of calcium qd
Co-intervention(s) * :
Compliance/Adherence: | | | 89%

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
16391587 | Mastaglia 2006 | primary | 25(OH)D

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
16391587 | Mastaglia 2006 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
16391587 | Mastaglia 2006 | Demographics (e.g., age, gender, race, education)? | Yes | age
16391587 | Mastaglia 2006 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no
16391587 | Mastaglia 2006 | Medical conditions
16391587 | Mastaglia 2006 | Medication
16391587 | Mastaglia 2006 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | Yes | season
16391587 | Mastaglia 2006 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no
16391587 | Mastaglia 2006 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure Category/Intervention Group | Crude or Adjusted analysis? | Mean Follow-up (months) | No. Analyzed | Baseline (median) | Baseline IQR | Final (median) | Final (IQR) | Net difference *** | Net difference CI/SE/SD * | P between groups ***
16391587 | Mastaglia 2006 | 25(OH)D at 2 mo | nmol/L | calcium only | crude | 2 mo | 13 | 45 | 31.2– 61.2 | 47.5 | 38.7– 66.2
| | | | calcium + 5000 D2 | | | 13 | 42 | 23.7–45 | 67.5 | 57.5– 91.2 | | | NS (btw 5000 & 10000)
| | | | calcium + 10000 D2 | | | 12 | 32.5 | 27.5– 37.5 | 97.7 | 79.1– 111.8
16391587 | Mastaglia 2006 | 25(OH)D at 3 mo | nmol/L | calcium only | crude | 3 mo | 13 | 45 | 31.2– 61.2 | 55 | 72.5– 68
| | | | calcium + 5000 D2 | | | 13 | 42 | 23.7–45 | 77.5 | 66.2– 156.2 | | | NS (btw 5000 & 10000)
| | | | calcium + 10000 D2 | | | 12 | 32.5 | 27.5– 37.5 | 97.7 | 79.3– 123.1

Duplicate one row per exposure category or intervention group. Please write “nd” if there was no data reported. DO NOT LEAVE BLANK.

* Please choose one and delete the others

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−” sign: e.g. +2.8 or −2.8

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
16391587 | Mastaglia 2006 | RCT | nd | nd | NA | Y | Y | N | N | Y | Y | C
Adverse Event(s): ** | | | | | | Hypercalciuria (n=1) in control group
Explanation for Overall Quality Grade (if not Grade A): | | | | | | small number of subjects in each group; methodology not fully explained

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Maxwell 1981

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
6793058 | Maxwell 1981 | RCT | pregnant Asians | nd | nd | - | government | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake...etc.)
6793058 | Maxwell 1981 | RCT | London, UK 51 N | 126 | 126 | nd | nd | 0 | Asians | weight at 3 ^ rd ^ trimester: 63.7 Kg | nd | 25(OH)D level at 28– 32 wk: 20.1 nmol/L

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
6793058 | Maxwell 1981 | 25(OH)D | | | | nd | | | | 25(OH)D level at 28–32 wk: 20.1 nmol/L
| | Dietary calcium intake | nd | nd | | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
6793058 | Maxwell 1981 | calciferol | nd | 1000 IU/d | 3 ^ rd ^ trimester only
| | placebo
Co-intervention(s) * :
Compliance/Adherence:

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
6793058 | Maxwell 1981 | primary | weight gain 3 ^ rd ^ trimester
| | secondary | birth weight

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
6793058 | Maxwell 1981 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
6793058 | Maxwell 1981 | Demographics (e.g., age, gender, race, education)? | no
6793058 | Maxwell 1981 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no
6793058 | Maxwell 1981 | Medical conditions
6793058 | Maxwell 1981 | Medication
6793058 | Maxwell 1981 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
6793058 | Maxwell 1981 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no
6793058 | Maxwell 1981 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | Result | 95% CI | P btw
6793058 | Maxwell 1981 | infants with birth weight <2500 g | calciferol | | 7 | 59 | | | | NS
6793058 | Maxwell 1981 | infants with birth weight <2500 g | control | | 15 | 67 | | | | NS

* Example: OR Ca/placebo

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline CI/SE/SD * | Final | Final SD * | Net difference | Net difference CI/SE/SD * | P between
6793058 | Maxwell 1981 | maternal weight gain 3 ^ rd ^ trimester | g/d | calciferol | | 59 | | | 63.3 | 20.7 | | | <0.001
6793058 | Maxwell 1981 | maternal weight gain 3 ^ rd ^ trimester | g/d | control | | 67 | | | 46.4 | 29.5
6793058 | Maxwell 1981 | infant birth weight | g | calciferol | | 59 | | | 3157 | 469 | | | NS
6793058 | Maxwell 1981 | infant birth weight | g | control | | 67 | | | 3034 | 524

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−” sign: e.g. +2.8 or −2.8

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
6793058 | Maxwell 1981 | Unclear how weight gain differences between groups were determined not due to edema.

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
6793058 | Maxwell 1981 | RCT | nd | nd | NA | Y | Y | Y | N | N | N | C
Adverse Event(s): ** | | | | | | no information provided
Explanation for Overall Quality Grade (if not Grade A): | | | | | | study methodology not completely reported; small sample size

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## McCullough 2003

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
12708719 | McCullough 2003 | Cohort study | Members of CPS II who resided in 21 states with population based cancer registries and were 50–74 years old at enrollment (when they completed a 10- page confidential, self-administered mailed questionnaire including questions on demographic, medical, behavioral, environmental, occupational, and dietary factors). A follow up questionnaire (beginning in 1997) was sent to cohort members to update exposure information and to ascertain newly diagnosed cancers. | Men and women lost to follow (until August 31, 1997); participants who reported any prevalent cancer (except non-melanoma skin cancer) at baseline; with extreme daily energy intake, for women <550 or >3500 kcal; for men <650 or >4000 kcal; those who left ≥ 10 of the 68 questionnaire items (15%) blank; respondents who left ≥ 4 of the seven dairy food questions blank; and those with uninterpretable responses to calcium or multivitamin questions; also, patients whose self-report of CRC could not be verified | 1992–1993 | Cancer Prevention Study (CPS) II Nutrition Cohort | nd | AT

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
12708719 | McCullough 2003 | Cohort study | US (21 states) | 127749 | 127749 | According to calcium intake per quintile For men, Q1: 62.9 (nd); Q3: 63.9 (nd); Q5: 65.1 (nd) For women, Q1: 61.3 (nd); Q3: 61.9 (nd); Q5: 62.6 (nd) | nd | 48 | nd | According to calcium intake per quintile %BMI>30 For men, Q1: 16.1; Q3: 13.6; Q5: 11.4 For women, Q1: 18.6; Q3: 16.5; Q5: 10.7 | According to calcium intake per quintile Median exercise MET score For men, Q1: 11.2; Q3: 13.4; Q5: 14.4 For women, Q1: 10.1; Q3: 12; Q5: 13.5 %long-term multivitamin use For men, Q1: 4.1; Q3: 12.1; Q5: 23.2 For women, Q1: 4.4; Q3: 15; Q5: 31 %family CRC history For men, Q1: 12.6; Q3: 12.3; Q5: 12.4 For women, Q1: 14.1; Q3: 14.4; Q5: 14.5 Median alcohol intake (g/day) For men, Q1: 17.3; Q3: 9.3; Q5: 6.4 For women, Q1: 6.1; Q3: 4.1; Q5: 3.7 | According to calcium intake per quintile Median total vitamin D (IU/day) For men, Q1: 94; Q3: 208; Q5: 488 For women, Q1: 92; Q3: 215; Q5: 485 According to vitamin D intake per quintile Median total calcium (mg/day) For men, Q1: 509; Q3: 872; Q5: 1122 For women, Q1: 496; Q3: 876; Q5: 1334

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data ...etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
12708719 | McCullough 2003 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | na | na | na | na | na
12708719 | McCullough 2003 | Dietary calcium intake | 68-item semi- quantitative FFQ (modification of the brief Health Habits and History Questionnaire (HHHQ) by Block et al. | USDA | y Validated using 4 random 24h recalls collected over a 1- year period. Energy adjusted correlation that controlled for day-to-day variation in 24h recalls was r=0.68 for dietary calcium | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
12708719 | McCullough 2003 | primary | Colorectal cancer | Confirmed incident cases of fatal or non-fatal colon cancer or rectal cancer that occurred between enrollment (1992–93) and August 31, 1997. Most cases were initially identified by self-report on the follow up questionnaires and verified by medical records, or from linkage with state cancer registries. Also, a few cases were initially identified through linkage with state cancer registries to confirm other reported cancers. CRC deaths were identified if recorded as the underlying or the contributory cause of death on a death certificate through August 31, 1997 among cohort members. Ascertainment of all deaths is accomplished through linkage with the National Death Index.
| | | Proximal colon cancer | Cancer at cecum to splenic flexure
| | | Distal colon cancer | Cancer at descending to sigmoid colon
| | | Rectal cancer | Cancer at rectum and rectosigmoid junction

UI | Author Year | Comments
12708719 | McCullough 2003 | Data on total energy intake are not given

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Conpfounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
12708719 | McCullough 2003 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes (total energy, %saturated fat intake, fruit intake, vegetable intake, long-term multivitamin use)
12708719 | McCullough 2003 | Demographics (e.g., age, gender, race, education)? | Yes (age; gender; education)
12708719 | McCullough 2003 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes (BMI)
12708719 | McCullough 2003 | Medical conditions | Yes (family CRC history)
12708719 | McCullough 2003 | Medication | Yes (for women only: HRT use )
12708719 | McCullough 2003 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | No
12708719 | McCullough 2003 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes (smoking; exercise METs)
12708719 | McCullough 2003 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

Age adjusted in five-year categories

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | Non- cases/Total N** | Mean Follow-up, mo | Crude or Adjusted analysis? | Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups*** | P for trend****
12708719 | McCullough 2003 | CRC | 1 ^ st ^ quintile of total calcium intake (mg/day) | | <561 | 156 | nd | nd | adjusted | RR | 1.00 | | nd | <0.06
| | | 2 ^ nd ^ quintile of total calcium intake (mg/day) | | 561–731 | 165 | nd | nd | adjusted | RR | 1.18 | nd | nd | <0.06
| | | 3 ^ rd ^ quintile of total calcium intake (mg/day) | | 732–925 | 137 | nd | nd | adjusted | RR | 0.96 | nd | nd | <0.06
| | | 4 ^ th ^ quintile of total calcium intake (mg/day) | | 926–1255 | 108 | nd | nd | adjusted | RR | 0.75 | nd | nd | <0.06
| | | 5 ^ th ^ quintile of total calcium intake (mg/day) | | >1255 | 117 | nd | nd | adjusted | RR | 0.87 | nd | nd | <0.06

Adjusted for age, smoking, BMI, education, exercise METs, family CRC history, total energy, %saturated fat intake, fruit intake, vegetable intake, long-term multivitamin use, and gender

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non- cases/Total N ** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups *** | P for trend ****
12708719 | McCullough 2003 | CRC | 1 ^ st ^ quintile of total calcium intake (mg/day) | | <561 | 156 | nd | nd | adjusted | RR | 1.00 | | nd | 0.02
| | | 2 ^ nd ^ quintile of total calcium intake (mg/day) | | 561–731 | 165 | nd | nd | adjusted | RR | 1.05 | 0.84–1.31 | nd | 0.02
| | | 3 ^ rd ^ quintile of total calcium intake (mg/day) | | 732–925 | 137 | nd | nd | adjusted | RR | 0.88 | 0.70–1.12 | nd | 0.02
| | | 4 ^ th ^ quintile of total calcium intake (mg/day) | | 926–1255 | 108 | nd | nd | adjusted | RR | 0.72 | 0.56–0.93 | nd | 0.02
| | | 5 ^ th ^ quintile of total calcium intake (mg/day) | | >1255 | 117 | nd | nd | adjusted | RR | 0.87 | 0.67–1.12 | nd | 0.02

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
12708719 | McCullough 2003 | For women, results on subsite analyses for CRC were imprecise due to small number of cases; therefore, only results on subsite analyses for men are presented. Results for total calcium intake and CRC were unchanged when the first year of follow up was excluded from the analysis.

For men: age adjusted in five-year categories

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | No. of Non- cases/Total N** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups*** | P for trend****
12708719 | McCullough 2003 | CRC | 1 ^ st ^ quintile of total calcium intake (mg/day) | | <561 | 89 | nd | nd | adjusted | RR | 1.00 | | nd | 0.002
| | | 2 ^ nd ^ quintile of total calcium intake (mg/day) | | 561–731 | 106 | nd | nd | adjusted | RR | 0.95 | nd | nd | 0.002
| | | 3 ^ rd ^ quintile of total calcium intake (mg/day) | | 732–925 | 98 | nd | nd | adjusted | RR | 0.85 | nd | nd | 0.002
| | | 4 ^ th ^ quintile of total calcium intake (mg/day) | | 926–1255 | 70 | nd | nd | adjusted | RR | 0.63 | nd | nd | 0.002
| | | 5 ^ th ^ quintile of total calcium intake (mg/day) | | >1255 | 58 | nd | nd | adjusted | RR | 0.71 | nd | nd | 0.002

For women: age adjusted in five-year categories

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | No. of Non- cases/Total N** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups*** | P for trend****
12708719 | McCullough 2003 | CRC | 1 ^ st ^ quintile of total calcium intake (mg/day) | | <561 | 67 | nd | nd | adjusted | RR | 1.00 | | nd | 0.007
| | | 2 ^ nd ^ quintile of total calcium intake (mg/day) | | 561–731 | 59 | nd | nd | adjusted | RR | 1.07 | nd | nd | 0.007
| | | 3 ^ rd ^ quintile of total calcium intake (mg/day) | | 732–925 | 39 | nd | nd | adjusted | RR | 0.71 | nd | nd | 0.007
| | | 4 ^ th ^ quintile of total calcium intake (mg/day) | | 926–1255 | 38 | nd | nd | adjusted | RR | 0.64 | nd | nd | 0.007
| | | 5 ^ th ^ quintile of total calcium intake (mg/day) | | >1255 | 59 | nd | nd | adjusted | RR | 0.72 | nd | nd | 0.007

For men: adjusted for age, smoking, BMI, education, exercise METs, family CRC history, total energy, %saturated fat intake, fruit intake, vegetable intake, long-term multivitamin use

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | No. of Non- cases/Total N** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups*** | P for trend****
12708719 | McCullough 2003 | CRC | 1 ^ st ^ quintile of total calcium intake (mg/day) | | <561 | 89 | nd | nd | adjusted | RR | 1.00 | | nd | 0.04
| | | 2 ^ nd ^ quintile of total calcium intake (mg/day) | | 561–731 | 106 | nd | nd | adjusted | RR | 1.01 | 0.76–1.34 | nd | 0.04
| | | 3 ^ rd ^ quintile of total calcium intake (mg/day) | | 732–925 | 98 | nd | nd | adjusted | RR | 0.93 | 0.70–1.25 | nd | 0.04
| | | 4 ^ th ^ quintile of total calcium intake (mg/day) | | 926–1255 | 70 | nd | nd | adjusted | RR | 0.71 | 0.52–0.98 | nd | 0.04
| | | 5 ^ th ^ quintile of total calcium intake (mg/day) | | >1255 | 58 | nd | nd | adjusted | RR | 0.82 | 0.58–1.16 | nd | 0.04
| | Proximal colon cancer | 1 ^ st ^ quintile of total calcium intake (mg/day) | | <561 | 26 | nd | nd | adjusted | RR | 1.00 | | nd | 0.04
| | | 2 ^ nd ^ quintile of total calcium intake (mg/day) | | 561–731 | 36 | nd | nd | adjusted | RR | 1.13 | 0.68–1.88 | nd | 0.04
| | | 3 ^ rd ^ quintile of total calcium intake (mg/day) | | 732–925 | 26 | nd | nd | adjusted | RR | 0.81 | 0.47–1.42 | nd | 0.04
| | | 4 ^ th ^ quintile of total calcium intake (mg/day) | | 926–1255 | 23 | nd | nd | adjusted | RR | 0.77 | 0.43–1.47 | nd | 0.04
| | | 5 ^ th ^ quintile of total calcium intake (mg/day) | | >1255 | 13 | nd | nd | adjusted | RR | 0.57 | 0.28–1.13 | nd | 0.04
| | Distal colon cancer | 1 ^ st ^ quintile of total calcium intake (mg/day) | | <561 | 17 | nd | nd | adjusted | RR | 1.00 | | | 0.55
| | | 2 ^ nd ^ quintile of total calcium intake (mg/day) | | 561–731 | 26 | nd | nd | adjusted | RR | 1.25 | 0.67–2.31 | nd | 0.55
| | | 3 ^ rd ^ quintile of total calcium intake (mg/day) | | 732–925 | 31 | nd | nd | adjusted | RR | 1.51 | 0.83–2.77 | nd | 0.55
| | | 4 ^ th ^ quintile of total calcium intake (mg/day) | | 926–1255 | 15 | nd | nd | adjusted | RR | 0.77 | 0.38–1.57 | nd | 0.55
| | | 5 ^ th ^ quintile of total calcium intake (mg/day) | | >1255 | 13 | nd | nd | adjusted | RR | 1.00 | 0.47–2.13 | nd | 0.55
| | Total colon cancer | 1 ^ st ^ quintile of total calcium intake (mg/day) | | <561 | 64 | nd | nd | adjusted | RR | 1.00 | | | 0.02
| | | 2 ^ nd ^ quintile of total calcium intake (mg/day) | | 561–731 | 82 | nd | nd | adjusted | RR | 1.08 | 0.77–1.50 | nd | 0.02
| | | 3 ^ rd ^ quintile of total calcium intake (mg/day) | | 732–925 | 67 | nd | nd | adjusted | RR | 0.89 | 0.63–1.27 | nd | 0.02
| | | 4 ^ th ^ quintile of total calcium intake (mg/day) | | 926–1255 | 51 | nd | nd | adjusted | RR | 0.72 | 0.49–1.05 | nd | 0.02
| | | 5 ^ th ^ quintile of total calcium intake (mg/day) | | >1255 | 38 | nd | nd | adjusted | RR | 0.74 | 0.49–1.12 | nd | 0.02
| | Rectal cancer | 1 ^ st ^ quintile of total calcium intake (mg/day) | | <561 | 23 | nd | nd | adjusted | RR | 1.00 | | nd | 0.71
| | | 2 ^ nd ^ quintile of total calcium intake (mg/day) | | 561–731 | 22 | nd | nd | adjusted | RR | 0.78 | 0.43–1.41 | nd | 0.71
| | | 3 ^ rd ^ quintile of total calcium intake (mg/day) | | 732–925 | 29 | nd | nd | adjusted | RR | 1.02 | 0.58–1.79 | nd | 0.71
| | | 4 ^ th ^ quintile of total calcium intake (mg/day) | | 926–1255 | 16 | nd | nd | adjusted | RR | 0.60 | 0.31–1.16 | nd | 0.71
| | | 5 ^ th ^ quintile of total calcium intake (mg/day) | | >1255 | 19 | nd | nd | adjusted | RR | 1.01 | 0.53–1.93 | nd | 0.71

For women: adjusted for age, smoking, BMI, education, exercise METs, family CRC history, total energy, %saturated fat intake, fruit intake, vegetable intake, long-term multivitamin use, and HRT use

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | No. of Non- cases/Total N** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups*** | P for trend****
12708719 | McCullough 2003 | CRC | 1 ^ st ^ quintile of total calcium intake (mg/day) | | <561 | 67 | nd | nd | adjusted | RR | 1.00 | | nd | 0.31
| | | 2 ^ nd ^ quintile of total calcium intake (mg/day) | | 561–731 | 59 | nd | nd | adjusted | RR | 1.16 | 0.82–1.66 | nd | 0.31
| | | 3 ^ rd ^ quintile of total calcium intake (mg/day) | | 732–925 | 39 | nd | nd | adjusted | RR | 0.80 | 0.54–1.21 | nd | 0.31
| | | 4 ^ th ^ quintile of total calcium intake (mg/day) | | 926–1255 | 38 | nd | nd | adjusted | RR | 0.78 | 0.51–1.18 | nd | 0.31
| | | 5 ^ th ^ quintile of total calcium intake (mg/day) | | >1255 | 59 | nd | nd | adjusted | RR | 0.94 | 0.63–1.39 | nd | 0.31

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | Statistical Analysis | | Outcome | | Design
12708719 | McCullough 2003 | a) Eligibility criteria clear? (y/n) | y | a) Exposure assessor blinded to outcome info? (y/n) | n | a) Method reported? (y/n) | y | a) One of the prespecified methods *** was used? (y/n) | na | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | a) Clear definition of outcome, including time of ascertainment? (y/n) | y | a) Prospective collection of data? (y/n) | y
12708719 | McCullough 2003 | b) Sampling of population random or consecutive? (y/n) | n | b) Outcome assessor blinded to exposure measurement? (y/n) | n | b) Food composition database or suppl composition reported? (y/n) | y | Time from sample collection to sample analysis reported? (y/n) | na | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | b) Loss to follow-up <20%? (y/n) | y | b) Analysis was planned when cohort was formed? (y/n) | y
12708719 | McCullough 2003 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | y | | | | b) Justification of final adjusted model selection? (y/n) | y | c) Do the authors specify a primary outcome? (y/n) | y | c) Justification of sample size (includes sample size calculations)? (y/n) | n
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Initial cohort was assembled to evaluate cancer mortality; assessor blinding not reported; power calculation not reported; results are not given sufficiently (age adjusted model without CI; number of non-cases per calcium quintile not provided); confirmation of cases by histology not reported

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## McCullough 2005

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
16365007 | McCullough 2005 | Cohort study | Women from the CPS II Nutrition Cohort, a prospective study of cancer mortality established in 1982. | Women who were lost to follow-up between enrollment in 1992/1993 and August 31, 2001 (n = 3,514), or, who, at baseline, reported a history of breast cancer (n = 6,220) or other cancer (except nonmelanoma skin cancer; n = 5,805). Women who were premenopausal or perimenopausal at baseline (n = 4,448) or with unknown menopausal status(n = 233); women who reported extreme values of daily energy intake (<500 or >3,500 kcal/d), or FFQs with z15% of the 68 questions blank (n = 7,345). Women with missing or uninterpretable responses for more than four dairy products (n = 85), calcium supplements (n = 952), or multivitamin use (n = 543), or women who reported both greater than six servings of milk per day and identical responses for two types of milk (n = 42) were also excluded. Finally, women were excluded if diagnosis date was unknown (n = 32). | 1992–1993 | CPS II Nutrition Cohort | nd | GR

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake...etc.)
16365007 | McCullough 2005 | Cohort study | US 30° N | 97,786 | 68,567 | 63 (nd) | nd | 0 | nd | Mean body mass index in 1992 = 26 Mean weight gain since age 18 y = 26 to 31 (units nd) | Current smoker 5 to 13% Nulliparous 7.5 % First birth after age 30 y 7 to 8% Current HRT use 26 to 48% | Total calcium (mg/d) = 706–1544 Total vitamin D (IU/d) 220–500 Calories (kcal/d) 1218–1693 Total fat (g/d) 39–57 Alcohol (g/d) 3.3–7.0

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
16365007 | McCullough 2005 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | nd | nd | | Total vitamin D (IU/d) included intake from diet and multivitamins (estimated to be 400 IU per pill). Nutrient estimates were adjusted for total energy using the residuals method
| | Dietary calcium intake | FFQ modified from Questionnaire developed by Block et al. | Diet Analysis System version 3.8a | Yes. validated using four random 24- hour recalls collected over a 1-year period as the comparison measure among 441 Nutrition Cohort participants | | | | | 68-item food frequency questionnaire (FFQ), which is a modification of the brief Health Habits and History Questionnaire developed by Block et al.

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
16365007 | McCullough 2005 | nd | Incident breast cancer | New diagnosis of either non fat al or fat al breast cancer that occur red after enrollment in 1992 or 1993 and before August 31, 2001. Breast cancer as a contributing cause of death among cohort members was ascertained through linkage with the National Death Index. ER and progesterone receptor (PR) status of the tumors was obtained through medical record reports and through state cancer registries when available.

UI | Author Year | Comments
16365007 | McCullough 2005 | “Potential effect modification of findings by potential for skin synthesis of vitamin D was examined by stratifying on UV index by state of residence for the subgroup of women (95.5%) who reported the same state of residence in 1982 and 2001. UV index levels were estimated using the 1997 monthly mean UV indices for major forecast cities in 50 states”

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must be explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
16365007 | McCullough 2005 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | stratified by ER status of the tumor, multivitamin use (current versus not current use), dietary fat intake (tertiles)
16365007 | McCullough 2005 | Demographics (e.g., age, gender, race, education)? | Yes (age at menarche, age at menopause, age at child birth, race)
16365007 | McCullough 2005 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes [height (<63, 63 to <65, 65 to <67, 67 in, missing height), weight gain since age 18]
16365007 | McCullough 2005 | Medical conditions | history of breast cyst
16365007 | McCullough 2005 | Medication Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | Skin synthesis of vitamin D was examined by stratifying on UV index by state of residence for the subgroup of women
16365007 | McCullough 2005 | Smoking and other life styles variables | Yes (alcohol consumption, hormone replacement therapy, current combined replacement therapy, past combined replacement therapy)
16365007 | McCullough 2005 | Other | family hx of breast cancer in a mother or sister

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Follow- up | Mean Ca level/ | No. of Cases (Event) * | Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups *** | P for trend ****
16365007 | McCullough 2005 | Breast cancer | ≤500 | 8y | ≤500 | 457 | 10,620 | Adjusted analysis | RR | 1.00 | | NS | 0.07
| | | >500–≤750 | 8y | >500–≤750 | 729 | 17,880 | Adjusted analysis | RR | 0.91 | (0.81–1.02) | NS
| | | >750–≤1000 | 8y | >750–≤1000 | 581 | 14,023 | Adjusted analysis | RR | 0.92 | (0.81–1.04) | NS
| | | >1,000–≤1,250 | 8y | >1,000–≤1,250 | 407 | 9,120 | Adjusted analysis | RR | 0.97 | (0.85–1.11) | NS
| | | >1250–≤1500 | 8y | >1250–≤1500 | 248 | 6,296 | Adjusted analysis | RR | 0.84 | (0.72–0.98) | .05
| | | >1500–≤1750 | 8y | >1500–≤1750 | 144 | 3,983 | Adjusted analysis | RR | 0.76 | (0.63–0.92) | .05
| | | >1750 | 8y | >1750 | 289 | 6,645 | Adjusted analysis | RR | 0.91 | (0.79–1.06) | NS

Multivariate-adjusted model controlling for age, energy, history of breast cyst, family history of breast cancer, height, weight gain since age 18, alcohol use, race, age at menopause, age at first birth and number of live births, education, mammography history, and HRT.

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = − 6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
16365007 | McCullough 2005 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | N | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | N | a) Level of the exposure in comparative categories (e.g. quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
16365007 | McCullough 2005 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | N | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | Y | a) Level of the exposure in comparative categories (e.g. quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | N | b) Analysis was planned when cohort was formed? (y/n) | N
16365007 | McCullough 2005 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Y | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | N | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Lot of samples excluded at the analysis phase; no biomarker uses

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Melamed 2008

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
18695076 | Melamed 2008 | Cohort study | Adults 20 years or older who had a physical exam and lab testing at baseline (Oct 1988–Oct 1994) and for whom vital status information was known during the follow-up period (through Dec 31, 2000) | Did not have complete data on the study variables of interest | Oct 1988–Oct 1994 | NHANES III | NIH; PJ Schafer CVD Research fund | MC

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
18695076 | Melamed 2008 | Cohort study | nd (multiple cities in US) | 13331 | 13331 | 44.8 | >=20 | 46 | Non-Hispanic white: 72.9%, non-Hispanic black: 13.4%, Mexican American: 5.3%; other: 8.4% | Mean BMI: 26.85 | Diabetes: 7.4% History of CVD: 7.9% HTN: 25% Use of cholesterol- lowering med: 3% | Use of vitamin D supplement: 26.7%

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
18695076 | Melamed 2008 | 25(OH)D | | | | Diasorin radioimmunoassay (RIA) kit (Diasorin, Stillwater, Minnesota) | CV from quality control samples, 13%–19% | nd | Winter, Jan-Mar: 25% Spring, Apr-Jun: 25% Summer, Jul-Sep: 25% Fall, Oct-Dec: 25% | See results
| | Dietary calcium intake | nd | | | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
18695076 | Melamed 2008 | primary | All-cause mortality | Linked National Death Index records; selected death certificates were reviewed manually to validate the process.
| | Primary | CVD mortality | Cause-specific death was coded according to the ICD-9-CM for deaths occurring between 1988 and 1998, and according to the ICD-10 for to deaths occurring in 1999 and 2000. Including deaths due to hypertensive disease, ischemic heart disease, arrhythmia, heart failure, cerebrovascular disease, atherosclerosis or other disease of the arteries.
| | Primary | Cancer mortality | Including all malignant neoplasm deaths, deaths as respiratory and intrathoracic organs and genital organs, colorectal cancer, breast cancer, and prostate cancer.
| | primary | Infectious disease mortality | Including deaths from infectious and parasitic disease, meningitis, acute rheumatic fever, endocarditis, acute upper and lower respiratory tract infections including influenza and pneumonia, and urinary tract infections.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
18695076 | Melamed 2008 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Use of vitamin D supplementation
18695076 | Melamed 2008 | Demographics (e.g., age, gender, race, education)? | Yes | Age, sex, race, low SES status
18695076 | Melamed 2008 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI
18695076 | Melamed 2008 | Medical conditions | HTN, history of CVD, diabetes
18695076 | Melamed 2008 | Medication | Use of cholesterol-lowering medications
18695076 | Melamed 2008 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | Season
18695076 | Melamed 2008 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | Smoking, physical activity level
18695076 | Melamed 2008 | Other | HDL, total cholesterol, estimate GFR categories, serum albumin level, log albumin to creatinine ratio, log CRP level

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non-cases/Total N ** | Mean Follow-up | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
18695076 | Melamed 2008 | All-cause mortality | 25(OH)D Q1, ng/mL | >32.1 | | nd | nd | Median 8.7 (IRQ 7.1–10.2) yr | adj | RR | 1 | | | nd
| | | | 24.4–32.1 | | nd | nd | | Adj | RR | 0.93 | 0.79–1.10
| | | | 17.8–24.3 | | nd | nd | | Adj | RR | 1.06 | 0.89–1.24
| | | | <17.8 | | nd | nd | | adj | RR | 1.26 | 1.08–1.46
18695076 | Melamed 2008 | CVD mortality | 25(OH)D Q1, ng/mL | >32.1 | | nd | nd | | adj | RR | 1 | | | nd
| | | | 24.4–32.1 | | nd | nd | | Adj | RR | 0.83 | 0.65–1.07
| | | | 17.8–24.3 | | nd | nd | | Adj | RR | 0.88 | 0.69–1.14
| | | | <17.8 | | nd | nd | | adj | RR | 1.20 | 0.87–1.64
18695076 | Melamed 2008 | Cancer mortality | 25(OH)D Q1, ng/mL | >32.1 | | nd | nd | Median 8.7 (IRQ 7.1–10.2) yr | Adjusted for cancer and external causes of death models include age, sex, race, season, cigarette use, BMI, log CRFP, serum albumin, physical activity level, use of vit D suppl, and low SES | RR | 1 | | | nd
| | | | 24.4–32.1 | | nd | nd | | Adjusted for cancer and external causes of death models include age, sex, race, season, cigarette use, BMI, log CRFP, serum albumin, physical activity level, use of vit D suppl, and low SES | RR | 0.8 | 0.54–1.19
| | | | 17.8–24.3 | | nd | nd | | Adjusted for cancer and external causes of death models include age, sex, race, season, cigarette use, BMI, log CRFP, serum albumin, physical activity level, use of vit D suppl, and low SES | RR | 1.08 | 0.8–1.46
| | | | <17.8 | | nd | nd | | Adjusted for cancer and external causes of death models include age, sex, race, season, cigarette use, BMI, log CRFP, serum albumin, physical activity level, use of vit D suppl, and low SES | RR | 0.91 | 0.63–1.31
18695076 | Melamed 2008 | Infectious disease mortality | 25(OH)D Q1, ng/mL | >32.1 | | nd | nd | Median 8.7 (IRQ 7.1–10.2) yr | adj | RR | 1
| | | | 24.4–32.1 | | nd | nd | | Adj | RR | 1.01 | 0.53–1.93
| | | | 17.8–24.3 | | nd | nd | | Adj | RR | 0.87 | 0.43–1.74
| | | | <17.8 | | nd | nd | | adj | RR | 0.84 | 0.38–1.86

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
18695076 | Melamed 2008 | All-cause mortality | During a median 8.7 years of follow-up (IRQ, 7.1–10.2 years), there were 1806 deaths, of which 777 (43%) were ascribed to CVD, 424 (23%) were ascribed to cancers, 105 (6%) were ascribed to infectious causes, and 92 (5%) were ascribed to external causes of death. Of those who died of CVD, 590 (76%) died of atherosclerotic CVD, 145 (19%) of cerebrovascular disease, and 42 (5%) of congestive heart failure. Those who died had a mean age of 66.4 years and 46% were female, 58% were hypertensive, 19% had diabetes, and 32% had prior CVD.
18695076 | Melamed 2008 | All-cause mortality 25(OH)D deficiency: 25(OH)D levels <17.8 ng/mL | In multivariate models, increasing age, female sex, non-white race/ethnicity (particularly non-Hispanic black race/ethnicity), diabetes, current smoking and creasing BMI were all independently associated with an increased odds of being 25(OH)D deficient (ie, lowest quartile). Physical activity, vitamin D supplementation, and non-winter season were associated with a decreased odds of deficiency.
18695076 | Melamed 2008 | All-cause mortality Subgroup analysis by CVD (present or absent) | The lowest 25(OH)D quartile was more strongly associated with mortality among participants without a history of CVD (MRR, 1.54; 95% CI, 1.23–1.94) than in those with a history of CVD (MRR, 0.90; 95% CI, 0.66–1.22) (P value for interaction, .006).
18695076 | Melamed 2008 | All-cause mortality Subgroup analysis by HTN (present or absent) | Stronger associations, although nonsignificant, were found for participants without hypertension (P value for interaction, .09)
18695076 | Melamed 2008 | All-cause mortality Subgroup analysis by DM (present or absent) | Stronger associations, although nonsignificant, were found for participants without diabetes (P value for interaction, .09)
18695076 | Melamed 2008 | All-cause mortality Subgroup analysis by various risk factors of low 25(OH)D level | No interaction was observed for age, race, obesity, physical activity level, smoking, or eGFR

Subgroup Analyses

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | Total N** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups*** | P for trend****
18695076 | Melamed 2008 | All-cause mortality | 25(OH)D Q1, ng/mL – men only | >32.1 | | 1047 | 6277 | adj | RR | 1 | | P=0.06 for interaction between sex | nd
| | | | 24.4–32.1 | | 1047 | 6277 | Adj | RR | 0.82 | 0.64–1.05
| | | | 17.8–24.3 | | 1047 | 6277 | Adj | RR | 0.94 | 0.75–1.19
| | | | <17.8 | | 1047 | 6277 | adj | RR | 1.04 | 0.83–1.30
18695076 | Melamed 2008 | All-cause mortality | 25(OH)D Q1, ng/mL – women only | >32.1 | | 759 | 7054 | adj | RR | 1 | | P=0.06 for interaction between sex | nd
| | | | 24.4–32.1 | | 759 | 7054 | Adj | RR | 1.16 | 0.87–1.55
| | | | 17.8–24.3 | | 759 | 7054 | Adj | RR | 1.27 | 0.97–1.66
| | | | <17.8 | | 759 | 7054 | adj | RR | 1.55 | 1.15–1.98
18695076 | Melamed 2008 | All-cause mortality | 25(OH)D Q1, ng/mL – age ≥65 yr | >32.1 | | 1047 | 6277 | adj | RR | 1 | | P=0.014 for interaction between age groups | nd
| | | | 24.4–32.1 | | 1047 | 6277 | Adj | RR | 0.97 | 0.79–0.82
| | | | 17.8–24.3 | | 1047 | 6277 | Adj | RR | 0.99 | 0.82–1.20
| | | | <17.8 | | 1047 | 6277 | adj | RR | 1.26 | 1.03–1.54
18695076 | Melamed 2008 | All-cause mortality | 25(OH)D Q1, ng/mL – age <65 | >32.1 | | 563 | 10464 | adj | RR | 1 | | P=0.014 for interaction between age groups | nd
| | | | 24.4–32.1 | | 563 | 10464 | Adj | RR | 0.81 | 0.58–1.14
| | | | 17.8–24.3 | | 563 | 10464 | Adj | RR | 1.13 | 0.81–1.56
| | | | <17.8 | | 563 | 10464 | adj | RR | 1.28 | 0.93–1.76

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
18695076 | Melamed 2008 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | Y | a) Method reported? (y/n) | NA | a) One of the prespecified methods *** was used? (y/n) | Y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
18695076 | Melamed 2008 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | NA | Time from sample collection to sample analysis reported? (y/n) | N | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
18695076 | Melamed 2008 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | NA | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Insufficient data, number of deaths per 25(OH)D quartile was not reported

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Mishra 2008

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
18827811 | Mishra 2008 | Cohort study | Women from the Medical MRC NSHD, a British national representative sample of men and women cohort followed from their birth in March 1946. | Men from the cohort | Since 1946 at birth – ages 53 y | Medical MRC NSHD, UK | Gov | GR

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
18827811 | Mishra 2008 | Cohort study | 54 N | 1471 | 1161 | 51.5 | ND | 0 | ND | ND | ND | Intake levels available as categories for ages 4, 36, 43, 53

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed information as possible on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
18827811 | Mishra 2008 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | No
18827811 | Mishra 2008 | Dietary calcium intake | 5-day food diaries | McCance and Widdowson's food table | ND | NA | N | | No | ND

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
18827811 | Mishra 2008 | ND | Mammography density | Ratio of the absolute area of dense tissue to the sum of the absolute areas of dense and non-dense tissues.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
18827811 | Mishra 2008 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes | Total energy intake
18827811 | Mishra 2008 | Demographics (e.g., age, gender, race, education)? | Yes | age at the time of mammogram; age at menarche; social class during adult life
18827811 | Mishra 2008 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | at the age of 53 y
18827811 | Mishra 2008 | Medical conditions | Yes | Menopausal status at the time of mammogram
18827811 | Mishra 2008 | Medication | Yes | Hormonal use
18827811 | Mishra 2008 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | No
18827811 | Mishra 2008 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | Smoking status
18827811 | Mishra 2008 | Other | Yes | Mammographic view

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca intake mg/d | No. of Cases (Event) * | Total N ** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
18827811 | Mishra 2008 | Mammographic density at age 36 y | Q1 | | ≤523 | 133 | 766 | ~32 y | Adj | β coefficient | Ref=1 | Ref=1 | | NS
| | | Q2 | | 524 – 648 | 143 | 766 | ~32 y | Adj | β coefficient | −0.11 | −0.33, 0.10
| | | Q3 | | 652 – 784 | 156 | 766 | ~32 y | Adj | β coefficient | −0.05 | −0.27, 0.17
| | | Q4 | | 785 – 940 | 160 | 766 | ~32 y | Adj | β coefficient | −0.04 | −0.27, 0.19
| | | Q5 | | ≥941 | 174 | 766 | ~32 y | Adj | β coefficient | −0.08 | −0.32, 0.17
18827811 | Mishra 2008 | Mammographic density at age 43 y | Q1 | | ≤611 | 145 | 755 | ~39 | Adj | β coefficient | Ref=1 | Ref=1 | | NS
| | | Q2 | | 612– 735 | 156 | 755 | ~39 | Adj | β coefficient | −0.13 | −0.35, 0.09
| | | Q3 | | 736– 859 | 145 | 755 | ~39 | Adj | β coefficient | −0.06 | −0.29, 0.17
| | | Q4 | | 860– 1020 | 156 | 755 | ~39 | Adj | β coefficient | −0.11 | −0.34, 0.12
| | | Q5 | | ≥1021 | 153 | 755 | ~39 | Adj | β coefficient | −0.16 | −0.42, 0.09

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
18827811 | Mishra 2008 | a) Eligibility criteria clear? (y/n) | y | a) Exposure assessor blinded to outcome info? (y/n) | n | a) Method reported? (y/n) | y | a) One of the prespecified methods *** was used? (y/n) | n | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | a) Clear definition of outcome, including time of ascertainment? (y/n) | y | a) Prospective collection of data? (y/n) | y
18827811 | Mishra 2008 | b) Sampling of population random or consecutive? (y/n) | y | b) Outcome assessor blinded to exposure measurement? (y/n) | n | b) Food composition database or suppl composition reported? (y/n) | y | Time from sample collection to sample analysis reported? (y/n) | na | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | b) Loss to follow-up <20%? (y/n) | Y (<13%) | b) Analysis was planned when cohort was formed? (y/n) | n
18827811 | Mishra 2008 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | nd | | | | | b) Justification of final adjusted model selection? (y/n) | y | c) Do the authors specify a primary outcome? (y/n) | n | c) Justification of sample size (includes sample size calculations)? (y/n) | n
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Missing table 1 on demographics, baseline exposure data

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Mitrou 2007

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17106437 | Mitrou 2007 | Cohort study | male smokers (≥5 cigarettes/d); 50–69 y | previous history of cancer (except for non-melanoma skin cancer or carcinoma in situ); serious diseases that limited long term participation; used vit E, A, or β- carotene >pre-defined dose; anticoagulant use | 1985–1988 | Alpha-Tocopherol, Beta-Carotene (ATBC) Cancer Prevention Study | NIH | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake...etc.)
17106437 | Mitrou 2007 | Cohort study | Finland 64°N | 29133 | 27028 | 56.7 (est.) | nd | 100 | Caucasians | BMI 26.5 (est.) | smokers at baseline | vit D 5.4 μg/d mean intake (est.)

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | | | | nd
17106437 | Mitrou 2007 | Dietary calcium intake | 276 item FFQ past 12 mo | database of the Natl Public Health Institute, Finland | Yes, intraclass correlation of FFQ 3 mo apart in a sample of 133 ranged from 0.6 to 0.7 | | | | | dietary calcium=1513 mg/d (est.)

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17106437 | Mitrou 2007 | primary | prostate cancer | Finnish Cancer Registry (medical records reviewed to confirm diagnosis through 4/1999)

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17106437 | Mitrou 2007 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes | total energy intake
17106437 | Mitrou 2007 | Demographics (e.g., age, gender, race, education)? | Yes | age, education
17106437 | Mitrou 2007 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI; Ht
17106437 | Mitrou 2007 | Medical conditions | Yes | type 2 DM
17106437 | Mitrou 2007 | Medication
17106437 | Mitrou 2007 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
17106437 | Mitrou 2007 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | physical activity; smoke inhalation, number of cigarettes
17106437 | Mitrou 2007 | Other | Yes | FH of prostate cancer; marital status; urban residence; intervention group

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Event * | No. of Non- cases/Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
17106437 | Mitrou 2007 | total prostate cancer | <1000 mg/d dietary calcium | nd | <1000 mg | 151 | nd | adjusted (age, intervention group, physical activity, type 2 DM, FH of prostate cancer, ht, BMI, smoking inhalation, cigarettes, marital status, education, urban residence, total energy intake) | RR | 1.0 | | | <0.0001
| | | 1000–1499 | | 1000–1499 | 611 | nd | | | 1.28 | 1.07–1.54
| | | 1500–1999 | | 1500–1999 | 402 | nd | | | 1.38 | 1.14–1.67
| | | ≥2000 | | ≥2000 | 103 | nd | | | 1.63 | 1.27–2.10

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
17106437 | Mitrou 2007 | prostate cancer subgroups | see Table II in paper for nonadvanced, advanced, low grade, high grade prostate cancer

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
17106437 | Mitrou 2007 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | N | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | N
17106437 | Mitrou 2007 | b) Sampling of population random or consecutive? (y/n) | nd | b) Outcome assessor blinded to exposure measurement? (y/n) | N | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
17106437 | Mitrou 2007 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Y | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | A
Explanation for Overall Quality Grade (if not Grade A):

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Morley 2006

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
16352684 | Morley 2006 | Cohort study | Pregnant <16 wk gestation | multiple pregnancies; maternal diseases; dark skin or concealing clothing; intention to move from the area in the foreseeable future | 2002–2003 | - | government | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
16352684 | Morley 2006 | Cohort study | Geelong, Australia 38 S | 475 | 374 | 29 | nd | 0 | 99% white | Ht 166 cm | nd | 25(OH)D in winter: 49.2 nmol/L; summer: 62.6 nmol/L (~11 wk (median) gestation)

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
16352684 | Morley 2006 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | RIA | y; CV 10.2% | nd | winter and summer | 25(OH)D in winter: 48.3 nmol/L; summer: 68.9 nmol/L (28–32 wk gestation)
| | Dietary calcium intake | nd | nd | nd | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
16352684 | Morley 2006 | primary | birth weight
| | | gestation length
| | | crown-heel length

Duplicate one row per outcome of interest. only neet to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
16352684 | Morley 2006 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
16352684 | Morley 2006 | Demographics (e.g., age, gender, race, education)? | Yes | infant sex
16352684 | Morley 2006 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | maternal height
16352684 | Morley 2006 | Medical conditions | | parity
16352684 | Morley 2006 | Medication
16352684 | Morley 2006 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | | season of blood drawn
16352684 | Morley 2006 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | smoking
16352684 | Morley 2006 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure Category/Intervention Group | Crude or Adjusted analysis? | Mean Follow-up (months) | No. Analyzed | Baseline | Baseline CI/SE/SD * | Final ** | Final SD * | Net difference *** | Net difference CI/SE/SD * | P between groups ***
16352684 | Morley 2006 | birth weight | g | maternal vit D at 28–32 wk <28 nmol/L | adj | | 27 | | | 3397 | 57 | −153 | −348, 42 | NS
| | | | ≥28 nmol/L | | | 347 | | | 3555 | 52
| | crown- heel length | cm | maternal vit D at 28–32 wk <28 nmol/L | | | 27 | | | 49.8 | 2.7 | −0.6 | −1.5, 0.3 | NS
| | | | ≥28 nmol/L | | | 347 | | | 50.4 | 2.4

Duplicate one row per exposure category or intervention group. Please write “nd” if there was no data reported. DO NOT LEAVE BLANK.

* Please choose one and delete the others

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
16352684 | Morley 2006 | | no associations between maternal 25(OH)D at recruitment (median 11 wk) and any birth measure (data not shown)
| | | see Table 3 in paper for results on gestation length; knee-heel length, and others

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
16352684 | Morley 2006 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | N | a) Method reported? (y/n) | N | a) One of the prespecified methods *** was used? (y/n) | Y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | N | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
16352684 | Morley 2006 | b) Sampling of population random or consecutive? (y/n) | N | b) Outcome assessor blinded to exposure measurement? (y/n) | N | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | N | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | N | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | N | b) Analysis was planned when cohort was formed? (y/n) | Y
16352684 | Morley 2006 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | Y
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | recruited only 475/2470 (19%) of potentially eligible women

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Morris 2001

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
11262466 | Morris 2001 | Cohort study | pregnant women | nd | nd | Calcium for Preeclampsia Prevention Study (CPEP) | NICHHD | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
11262466 | Morris 2001 | Cohort study | Albuquerque, NM; Birmingham, AL; Cleveland, OH; Memphis, TN; Portland OR | 4314 | 4157 | 79% age 17–24 | nd | 0 | 51% white; 46% African American | 38% with BMI ≥26 | nd | dietary calcium pre-intervention: 1121 mg/d

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | | | | nd
11262466 | Morris 2001 | Dietary calcium intake | 24 h recall | nd | n | | | | | dietary calcium pre- intervention: 1121 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
11262466 | Morris 2001 | primary | preeclampsia | HTN (DBP≥90 mm) and proteinuria (≥300 mg) within 7 d of each other

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
11262466 | Morris 2001 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
11262466 | Morris 2001 | Demographics (e.g., age, gender, race, education)? | Yes | race
11262466 | Morris 2001 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI
11262466 | Morris 2001 | Medical conditions
11262466 | Morris 2001 | Medication
11262466 | Morris 2001 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
11262466 | Morris 2001 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | smoking
11262466 | Morris 2001 | Other | | health insurance coverage

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non- cases/Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
11262466 | Morris 2001 | preeclampsia | dietary calcium | | 579 | ND | ND | adj | RR | 1.00 (ref) | | NS | ND
| | | | | 580–845 | ND | ND | | | 0.90 | 0.61–1.30
| | | | | 846–1131 | ND | ND | | | 0.95 | 0.65–1.39
| | | | | 1132–1560 | ND | ND | | | 0.97 | 0.65–1.45
| | | | | 1561 | ND | ND | | | 0.78 | 0.49–1.24
11262466 | Morris 2001 | Pregnancy- induced hypertension | dietary calcium | | 579 | ND | ND | adj | RR | 1.00 (ref) | | NS | ND
| | | | | 580–845 | ND | ND | | | 1.09 | 0.84–1.42
| | | | | 846–1131 | ND | ND | | | 1.10 | 0.83–1.44
| | | | | 1132–1560 | ND | ND | | | 1.14 | 0.85–1.53
| | | | | 1561 | ND | ND | | | 1.35 | 0.98–1.86

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
11262466 | Morris 2001 | “Because the randomized trial from which the data were obtained did not demonstrate any effect of treatment with supplemental calcium, models were fitted to data pooled across both treatment arms.”

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
11262466 | Morris 2001 | a) Eligibility criteria clear? (y/n) | N | a) Exposure assessor blinded to outcome info? (y/n) | N | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
11262466 | Morris 2001 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | N | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | N | b) Loss to follow-up<20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
11262466 | Morris 2001 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | unclear if the analysis was also adjusted for total energy intake

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Moschonis 2006

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17181890 | Moschonis 2006 | RCT | Greek postmenopausal women | Women diagnosed having a T-score lower than − 2.5, taking medications (i.e. thiazide diuretics, glucocortocoids) and/or dietary supplements (calcium, magnesium, phosphate or vitD) that affect bone metabolism, having any kind of degenerative chronic disease (i.e. diabetes, nephrolithiasis, heart disease, cancer, hyper-and hypothyroidism, impaired renal and liver function), smoking and being at menopause for less than 1 y, osteoporotic, or having abnormal values on aforementioned blood indices. | 2004 | nd | Friesland Foods Hellas | JHL MC

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
17181890 | Moschonis 2006 | RCT | Greece (Nea Smyrni, Kalluthea and Neo Iraklio) 31° N | 112 | 101 | 61 (nd) | 55–65 | 0% | 100% Greek | Weight - 72.9 kg Height – 157.2 cm BMI – 29.6 kg/m ^ 2 ^ | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
17181890 | Moschonis 2006 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | nd | nd | nd | VitD intake 0.59 μg/d
17181890 | Moschonis 2006 | Dietary calcium intake | 24hr recall | Database for Greek food and recipes (University of Crete) | nd | | | | | Ca 679.7 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
17181890 | Moschonis 2006 | Ca group | Supplementary Ca (87% of Calcium lactate gluconate 13% of Ca carbonate) | 600 mg | 12 mo
17181890 | Moschonis 2006 | Dairy group | Advised to consume 3 portions of low-fat dairy products (milk and yogurt) fortified with Ca and vitD3 on daily basis (1 portion=250 ml milk, 200g yogurt) | 400 mg calcium/portion (one portion is equal to 250 ml milk and to 200 g yogurt) and 2.5 ug vitamin D3 per portion. Total daily dose = 1200 mg Ca +7.5 ug vit D3 | 12 mo | Advice to consume dairy products on daily basis. In order to avoid excess caloric intake subjects were advised to substitute other dairy products in their diet with those provided
17181890 | Moschonis 2006 | Control group | No intervention, usual diet | Na | 12 mo | na
Co-intervention(s) * : | | | None
Compliance/Adherence: | | | Dairy group 93% (assessed via information obtained at the biweekly sessions, combined with data obtained from the nutritional assessments conducted at baseline, 5 and 12 months of intervention) Ca group 95% (assessed by checking for remaining ca tablets in the returned packages but also via weekly phone calls)

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17181890 | Moschonis 2006 | primary | BMD | DXA

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17181890 | Moschonis 2006 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
17181890 | Moschonis 2006 | Demographics (e.g., age, gender, race, education)? | no
17181890 | Moschonis 2006 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no
17181890 | Moschonis 2006 | Medical conditions
17181890 | Moschonis 2006 | Medication
17181890 | Moschonis 2006 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
17181890 | Moschonis 2006 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no
17181890 | Moschonis 2006 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure Category/Intervention Group | Crude or Adjusted analysis? | Mean Follow-up (months) | No. Analyzed | Baseline | Baseline SE * | Delta ** | Delta CI * | Net difference *** | Net difference CI * | P between groups ***
17181890 | Moschonis 2006 | Total body BMD | g/cm ^ 2 ^ | Control group | Crude | 12 m | 36 | 1.12 | 0.014 | −0.7 % | −1.4, −0.1 % | | | P<0.05, dairy vs. control
17181890 | Moschonis 2006 | Total body BMD | g/cm ^ 2 ^ | Calcium-Supplemented group | Crude | 12 m | 26 | 1.077 | 0.022 | 0.6 % | −0.4, 1.6 % | | | P<0.05, dairy vs. Ca group
17181890 | Moschonis 2006 | Total body BMD | g/cm ^ 2 ^ | Dairy group (1200 mg Ca +7.5 ug vit D3) | Crude | 12 m | 39 | 1.133 | 0.012 | 1.5 % | 0.9, 2.2 %

Duplicate one row per exposure category or intervention group. Please write “nd” if there was no data reported. DO NOT LEAVE BLANK.

* Please choose one and delete the others

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−” sign: e.g. +2.8 or −2.8

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
17181890 | Moschonis 2006 | RCT-Parallel | Y | N | N | N | N | Y | Y | N | Y | C
Adverse Event(s): ** | | | | | | bloating, constipation and intestinal discomfort apparently related to the calcium supplement
Explanation for Overall Quality Grade (if not Grade A): | | | | | | No blinding, no adjustment for confounders. Analyses only included completers: 11 subjects dropped out: 2 from the dairy group dropped out due to personal reasons, whereas 4 subjects from the control group either could not be tracked down or were not available to participate at follow-up examinations. Furthermore, 4 women from the calcium supplement group withdrew, due to complaints of side-effects, such as bloating, constipation and intestinal discomfort apparently related to the supplement used.

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Nagpal 2009

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
19125756 | Nagpal 2009 | RCT | Male, “apparently healthy”, centrally obese (waist circumference ≥ 78 cm), ≥ 35 yrs | Fasting plasma glucose > 7.0 mmol/L, self-reported diabetes, insulin or any oral glucose-lowering medication, resting BP > 140/90 mmHg self-reported hypertensive, antihypertensive medication, cholecalciferol or Ca supplementation in last 6 mo., chromic renal, hepatic, malignant or intestinal disease or renal stones, any medication within the last month that could influence insulin secretion, insulin sensitivity, vit D or Ca metabolism, febrile illness or infective morbidity in the last 10 days, grossly deranged liver or kidney function | 2006–2007 | nd | Indian Council of Medical Research, New Delhi | MB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
19125756 | Nagpal 2009 | RCT | New Delhi, India (28 N) | 100 | 71 (ITT analysis) 65 (per protocol analysis) | 44 (8) | nd | 100% | Indian | BMI = 26.4 (4) Waist circumference (cm) = 91.6 (9) Waist-hip ratio = 0.98 (0.06) | “apparently healthy”, centrally obese | Most subjects severely vit D deficient

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed information as possible on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
19125756 | Nagpal 2009 | 25(OH)D | | | | RIA | Yes: 5% of samples re-run for quality control. Mean-centered coeff of variation for 25(OH)D was 8.0% | nd | nd | Mean (nmol/L) ± SD in supplemented group = 36.5 ± 14.55. In control group = 30.0 ± 12.50
| | Dietary calcium intake | nd | nd | nd | nd | nd | | nd | Serum Ca (mmol/L) ± SD = 2.3 ± 0.20

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
19125756 | Nagpal 2009 | vit D | Calcirol (brand name of cholecalciferol from Cadila Pharmaceuticals, Ahmedabad, India) | 8571 IU cholecalciferol | 6 wk | 120,000 IU sachets given 3 times, every 2 weeks, for 6 weeks
| | placebo | Identical to vit D in color, taste, and external appearance and also provided by Cadila Pharmaceuticals | - | 6 wk | Placebo sachets given 3 times, every 2 weeks, for 6 weeks
Co-intervention(s) * : | | | Both groups advised to continue their normal diet and exercise.
Compliance/Adherence: | | | Supervised administration of doses by home visits

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
19125756 | Nagpal 2009 | 2° | SBP | Automated OMRON electronic device used – validated in an earlier trial. 3 serial BP recordings from the right arm were taken after 10 min rest at 10-min intervals in the sitting posture as per WHO recommendations, and the mean used for analysis.
| | 2° | DBP | Same as SBP
| | nd | 25(OH)D

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
19125756 | Nagpal 2009 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
19125756 | Nagpal 2009 | Demographics (e.g., age, gender, race, education)? | Yes – groups matched on age, gender, race, education, and income
19125756 | Nagpal 2009 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes – groups matched on BMI, waist circumference, waist-hip ratio
19125756 | Nagpal 2009 | Medical conditions
19125756 | Nagpal 2009 | Medication
19125756 | Nagpal 2009 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
19125756 | Nagpal 2009 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes – groups matched on smoking, alcohol, physical activity
19125756 | Nagpal 2009 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline SD * | Delta ** | Delta SD * | Net difference | Net difference SE * | P between
19125756 | Nagpal 2009 | SBP (ITT analysis) | mmHg | vit D | 1.5 | 35 | 124 | 11 | 0.60 | 9.82 | +3.95 | 2.05 | 0.058
19125756 | Nagpal 2009 | SBP (ITT analysis) | mmHg | placebo | 1.5 | 36 | 124 | 10 | −3.35 | 7.21
| | SBP (per protocol analysis) | mmHg | vit D | 1.5 | 32 | 124 | 11 | 0.60 | 9.82 | +3.68 | 2.06 | 0.079
| | SBP (per protocol analysis) | mmHg | placebo | 1.5 | 33 | 124 | 10 | −3.09 | 7.14
| | DBP (ITT) | mmHg | vit D | 1.5 | 35 | 78 | 8 | 0.43 | 7.66 | +1.69 | 1.64 | 0.305
| | DBP (ITT) | mmHg | placebo | 1.5 | 36 | 77 | 9 | −1.26 | 5.97
| | DBP (per protocol) | mmHg | vit D | 1.5 | 32 | 78 | 8 | 0.43 | 7.66 | +1.55 | 1.65 | 0.353
| | DBP (per protocol) | mmHg | placebo | 1.5 | 33 | 77 | 9 | −1.11 | 5.99
| | 25(OH)D (ITT) | nmol/L | vit D | 1.5 | 35 | 36.5 | 14.55 | 35.1 | 27.28 | +34.52 | 4.94 | <0.0005
| | 25(OH)D (ITT) | nmol/L | placebo | 1.5 | 36 | 30.0 | 12.50 | 0.60 | 11.61
| | 25(OH)D (per protocol) | nmol/L | vit D | 1.5 | 32 | 36.5 | 14.55 | 35.1 | 27.28 | +34.44 | 5.02 | <0.0005
| | 25(OH)D (per protocol) | nmol/L | placebo | 1.5 | 33 | 30.0 | 12.50 | 0.65 | 11.78
| | Weight (ITT) | Kg | vit D | 1.5 | 35 | nd | nd | +0.03 | 1.82 | +0.42 | 0.42 | 0.42
| | Weight (ITT) | Kg | placebo | 1.5 | 36 | nd | nd | −0.38 | 1.70
| | Weight (per protocol) | | vit D | 1.5 | 32 | nd | nd | +0.35 | 1.60 | +0.76 | 0.41 | 0.07
| | Weight (per protocol) | | placebo | 1.5 | 33 | nd | nd | −0.41 | 1.73
| | BMI (ITT) | kg/m ^ 2 ^ | vit D | 1.5 | 35 | 26.7 | 4.54 | −0.02 | 0.62 | +0.02 | 0.15 | 0.90
| | BMI (ITT) | kg/m ^ 2 ^ | placebo | 1.5 | 36 | 26.0 | 3.46 | −0.04 | 0.68
| | BMI (per protocol) | | vit D | 1.5 | 32 | 26.7 | 4.54 | +0.08 | 0.56 | +0.13 | 0.16 | 0.40
| | BMI (per protocol) | | placebo | 1.5 | 33 | 26.0 | 3.46 | −0.05 | 0.69

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
19125756 | Nagpal 2009 | RCT-parallel | Y | Y | NA | N | Y | Y | Y | Y | Y | B (Weight C)
Adverse Event(s): ** | | | | | | Both groups were advised to report any interval morbidity including nausea, vomiting, abdominal pain, urinary complaints, or muscle cramps or diagnosis of hypercalcemia during treatment of any illness. No specific data on AEs was provided.
Explanation for Overall Quality Grade (if not Grade A): | | | | | | 26% drop-out rate. However, authors claim that there is a low likelihood of loss to follow-up biasing results because 1) none of the baseline characteristics was significantly different between those reporting and those lost to follow-up, 2) the proportions of subjects lost to follow-up in both groups were comparable, and 3) interval morbidity in the two groups did not differ. No baseline data on weight.

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT–Parallel, RCT–Cross-over, RCT–Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse events.

## Nelson 2009

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
19158226 | Nelson 2009 | RCT | Women aged 19–35 y, living in the Bangor, ME area, subjects had a BMI 18.5~40kg/m ^ 2 ^ , have a baseline serum 25(OH)D concentration 22.5–175nmol/L, and be free of any disease or condition that influences Ca or Vit D, asked not to travel to a southern latitude (<35° N latitude) between September and March and to refrain from using tanning booths. Had not regularly consumed any Ca or Vit D-containing supplement within the previous 4 mo and agreed not to take any Ca, Vit D, or multivitamin supplements other than those provided during the study period. | Pregnant women, Women planned to become pregnant, subjects taking any medications, other than oral contraceptives, that affect Ca or Vit D | 2005 | nd | nd | JHL

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
19158226 | Nelson 2009 | RCT | Bangor, ME | 112 women | 86 women | 22.2 (3.7) | 19–35 y | 0 | Predominantly white women | BMI 25.9 % body fat 30.1% Height 164.2 cm Weight 69.7kg | Healthy | ND

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed information as possible on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
19158226 | Nelson 2009 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | RIA | Y, intra-assay and inter-assay CV, <10% | 1 month | September and February | Serum 25(OH)D 62.0nmol/L
19158226 | Nelson 2009 | Dietary calcium intake | 3-d food records | ND | n | nd | nd | | nd | Ca intake 908.2 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
19158226 | Nelson 2009 | Vit D3 | Vit D3 supplement | Vit D3 20 μg/d | 6 mo | One time/day
| Nelson 2009 | Placebo
Co-intervention(s) * : | | | Hormonal contraceptive
Compliance/Adherence: | | | Compliance was assessed by pill counts. No subject had compliance <75%

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
19158226 | Nelson 2009 | Primary | Serum 25(OH)D change

UI | Author Year | Comments
19158226 | Nelson 2009 | The actual mean D3 content of the capsules was 22 μg. There was a run-in period from Feb until Sep 2005.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
19158226 | Nelson 2009 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes | VitD intake, Ca intake
19158226 | Nelson 2009 | Demographics (e.g., age, gender, race, education)? | Yes * | Age
19158226 | Nelson 2009 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes * | BMI, total body fat %, height, weight
19158226 | Nelson 2009 | Medical conditions
19158226 | Nelson 2009 | Medication
19158226 | Nelson 2009 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | Yes | Summer sun exposure
19158226 | Nelson 2009 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no *
19158226 | Nelson 2009 | Other | Yes | Baseline 25(OH)D

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline CI/SE/SD * | Delta ** | Delta CI/SE/SD * | Net difference | Net difference CI/SE/SD * | P between
19158226 | Nelson 2009 | 25(OH)D | nmol/L | Vit D3 | 12 mo | 55 | 62.1 | 24.0 | 35.3 | 23.2 | 24.4 | nd | <0.0005
19158226 | Nelson 2009 | 25(OH)D | nmol/L | Placebo | 12 mo | 31 | 61.9 | 22.6 | 10.9 | 16.9

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
19158226 | Nelson 2009 | RCT-Parallel | nd | nd | NA | Y | nd | y | y | y | y | B
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Poor reporting of methods

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse events.

## Nomura 1998

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
9794175 | Nomura 1998 | Case-cohort study | men with available blood specimen at baseline | baseline prostate cancer; enrollment in cardiolipin study; previously thawed sample for other studies | 1967–1970 | Honolulu Heart Program | government | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
9794175 | Nomura 1998 | Case-cohort study | Oahu, Hawaii 21°N | 272 | 272 | 58 (nd) | 49–70 | 100 | Hawaiian Japanese | nd | 22 pack-years smoked | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
9794175 | Nomura 1998 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | protein-binding | Intra-assay CV 5 to 10% | ≥23 y | nd | all subjects live in Hawaii
| | Dietary calcium intake | nd | nd | | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
9794175 | Nomura 1998 | primary | prostate cancer | biopsy or surgical specimen; discharge records

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
9794175 | Nomura 1998 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | no
9794175 | Nomura 1998 | Demographics (e.g., age, gender, race, education)? | Yes (age, month & year of exam, education)
9794175 | Nomura 1998 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no
9794175 | Nomura 1998 | Medical conditions | no
9794175 | Nomura 1998 | Medication | no
9794175 | Nomura 1998 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | Yes, all from Hawaii
9794175 | Nomura 1998 | Smoking and other life styles variables | Yes (smoking; alcohol use)
9794175 | Nomura 1998 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases * | No. of Non-cases ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
9794175 | Nomura 1998 | prostate cancer | quartile of 25 OH-D | <34 ng/mL (based on controls freq) | | 38 | 34 | crude (conditional logistic) | OR | 1.0 (Ref) | | | 0.68
| | | | 34–40 | | 35 | 36 | | | 0.8 | 0.4–1.8
| | | | 41–47 | | 30 | 32 | | | 0.8 | 0.4–1.7
| | | | ≥48 | | 33 | 34 | | | 0.8 | 0.4–1.8
| | | quartile of 1,25 OH-D | <33 pg/mL | | 42 | 40 | crude (conditional logistic) | | 1.0 (Ref) | | | 0.87
| | | | 33–39 | | 32 | 30 | | | 1.0 | 0.5–2.1
| | | | 40–48 | | 28 | 34 | | | 0.7 | 0.3–1.6
| | | | ≥49 | | 34 | 32 | | | 1.0 | 0.5–2.1

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

MEAN DATA

THIS SHOULD ONLY APPLY TO CASE-COHORT STUDIES THAT COMPARE BASELINE VIT D/CA LEVELS BETWEEN CASES (WITH DISEASE) AND CONTROLS (WITHOUT DISEASE)

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Median 25(OH)D Level | Vit D level CI/SE/SD* | Mean Ca intake or Ca balance | Ca CI/SE/SD* | P between groups
9794175 | Nomura 1998 | Cases: | 6–26 y | crude | 136 | 41.0 ng/mL | | | | 0.66
| | Control: | 6–26 y | crude | 136 | 41.6

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Median 1, 25(OH)D Level | Vit D level CI/SE/SD* | Mean Ca intake or Ca balance | Ca CI/SE/SD* | P between groups
9794175 | Nomura 1998 | Cases: | 6–26 y | crude | 136 | 39.0 pg/mL | | | | 0.66
| | Control: | 6–26 y | crude | 136 | 39.5 | | | | 0.68

Duplicate one table per outcome

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
9794175 | Nomura 1998 | prostate cancer | 1. Overall results similar in 58 cases ≥75 y to 78 cases <75 y 2. Regressing the case-control difference on the month of exam showed a coefficient of −0.04 with a P of 0.92

UI | Author Year | Outcome | Results
9794175 | Nomura 1998 | prostate cancer by both 25 OH-D and 1,25 OH-D | Joint effect odds ratio

| 1, 25 OH-D tertile
25 OH-D tertile | 1 (16–34) | 2 (35–46) | 3 (47–74)
1 (21–36) | 1.0 (Ref) | 0.9 (0.3–2.6) | 1.0 (0.3–3.4)
2 (37–46) | 0.4 (0.1–1.2) | 0.7 (0.2–2.2) | 1.2 (0.4–3.6)
3 (47–92) | 1.5 (0.5–4.7) | 0.7 (0.2–2.3) | 0.5 (0.2–1.7)

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
9794175 | Nomura 1998 | a) Eligibility criteria clear? (y/n) | N | a) Exposure assessor blinded to outcome info? (y/n) | N | a) Method reported? (y/n) | N | a) One of the prespecified methods *** was used? (y/n) | N | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | N | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
9794175 | Nomura 1998 | b) Sampling of population random or consecutive? (y/n) | N | b) Outcome assessor blinded to exposure measurement? (y/n) | N | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | Y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | N | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
9794175 | Nomura 1998 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | unclear what factors were included in conditional logistic analysis; 34/170 cases were not included in the analysis because the diagnosis was within 5 years of their examination and had their sera sample thawed

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Oh 2007

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17379616 | Oh 2007 | Cohort study | Registered nurses 30–55y in the Unites States, who returned the 1980 FFQ, Participants who had no diagnosis of cancer (excluding nonmelanoma skin cancer), inflammatory bowel disease, familial polyposis, or colorectal polyp prior to 1980, who reported having undergone at least one colonoscopy or sigmoidoscopy between 1980 and 2002 | Nd | 1976 | The Nurses’ Health Study | National Institute of Health | JHL

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
17379616 | Oh 2007 | Cohort study | US (38° N) | 121700 | 48115 | nd | nd | 0% | nd | BMI 24 | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data...etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
17379616 | Oh 2007 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | nd | nd | nd | Nd
17379616 | Oh 2007 | Dietary calcium intake | FFQ | USDA | Yes, correlation coefficient btw 1980 dietary records and the 1984 FFQ: 0.56 for energy adjusted total Ca, 0.51 for dietary Ca | | | | | Ca Quintile 1; 510mg Quintile 3: 741mg Quintile 5: 946mg

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17379616 | Oh 2007 | nd | Colorectal adenoma | Reviewed the medical records the histologic type, the anatomic location, and the size of reported polyps, cases of distal colorectal adenoma confirmed by histopathologic report

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17379616 | Oh 2007 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Energy intake, energy-adjusted intakes of fiber, folate, phosphorus, and retinol, and red meat intake, vitD intake
17379616 | Oh 2007 | Demographics (e.g., age, gender, race, education)? | Yes - age
17379616 | Oh 2007 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes - BMI
17379616 | Oh 2007 | Medical conditions
17379616 | Oh 2007 | Medication | Postmenopausal hormone use, regular aspirin use
17379616 | Oh 2007 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
17379616 | Oh 2007 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes - pack years of smoking, alcohol consumption, vigorous physical activity
17379616 | Oh 2007 | Other | Family history of colorectal cancer, history of previous endoscopy, indication for endoscopy

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose ***** | No. of Cases (Event) * | No. of Non- cases/Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
17379616 | Oh 2007 | Adenoma | Ca quintile 1 | | 584 | nd | nd | Adjusted | RR | 1 | | | 0.06
| | | Ca quintile 2 | | 779 | nd | nd | Adjusted | RR | 1.05 | 0.93–1.20
| | | Ca quintile 3 | | 949 | nd | nd | Adjusted | RR | 0.96 | 0.84–1.11
| | | Ca quintile 4 | | 1139 | nd | nd | Adjusted | RR | 0.96 | 0.82–1.12
| | | Ca quintile 5 | | 1451 | nd | nd | Adjusted | RR | 0.88 | 0.74–1.04
17379616 | Oh 2007 | Distal colon cancer | Ca quintile 1 | | 584 | nd | nd | Adjusted | RR | 1 | | | 0.20
| | | Ca quintile 2 | | 779 | nd | nd | Adjusted | RR | 1.04 | 0.90–1.20
| | | Ca quintile 3 | | 949 | nd | nd | Adjusted | RR | 0.96 | 0.82–1.13
| | | Ca quintile 4 | | 1139 | nd | nd | Adjusted | RR | 0.97 | 0.82–1.16
| | | Ca quintile 5 | | 1451 | nd | nd | Adjusted | RR | 0.90 | 0.74–1.09
17379616 | Oh 2007 | Rectum cancer | Ca quintile 1 | | 584 | nd | nd | Adjusted | RR | 1 | | | 0.24
| | | Ca quintile 2 | | 779 | nd | nd | Adjusted | RR | 1.02 | 0.81–1.29
| | | Ca quintile 3 | | 949 | nd | nd | Adjusted | RR | 0.93 | 0.72–1.20
| | | Ca quintile 4 | | 1139 | nd | nd | Adjusted | RR | 0.91 | 0.69–1.21
| | | Ca quintile 5 | | 1451 | nd | nd | Adjusted | RR | 0.85 | 0.62–1.16

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

***** Median Ca level

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
17379616 | Oh 2007 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | nd | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | N | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
17379616 | Oh 2007 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | Y | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | N | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
17379616 | Oh 2007 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Y | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | N | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Power calculation not reported; cases, non-cases per calcium category not provided; exposure assessors blinding not reported

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Oken 2007

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17521921 | Oken 2007 | Cohort study | pregnancy | no outpatient medical records; did not complete 1 ^ st ^ trimester dietary questionnaire; preexisting chronic HTN and did not develop preeclampsia; missing covariate information | 1999–2002 | Project Viva | NIH and others | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
17521921 | Oken 2007 | Cohort study | MA 41° –42° N | 1718 | 1718 | 68% age 30 to <40 | nd | 0 | 72% white; 12% black | 67% prepregnancy BMI <24.9 | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | | | | nd
17521921 | Oken 2007 | Dietary calcium intake | semi-quantitative FFQ | Harvard (based on USDA) | n | | | | | calcium (dietary & supplement): 1308 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17521921 | Oken 2007 | primary | preeclampsia | BP >140/90 & proteinuria (dipstick 1+ ≥2 occasions or dipstick 2+) >4 h and ≤7 days apart
| | | gestational HTN

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17521921 | Oken 2007 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
17521921 | Oken 2007 | Demographics (e.g., age, gender, race, education)? | Yes | age; race; education
17521921 | Oken 2007 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | prepregnancy BMI
17521921 | Oken 2007 | Medical conditions | | 1 ^ st ^ trimester SBP; parity
17521921 | Oken 2007 | Medication
17521921 | Oken 2007 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
17521921 | Oken 2007 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no
17521921 | Oken 2007 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

MEAN DATA

THIS SHOULD ONLY APPLY TO CASE-COHORT STUDIES THAT COMPARE BASELINE VIT D/CA LEVELS BETWEEN CASES (WITH DISEASE) AND CONTROLS (WITHOUT DISEASE)

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Mean 25(OH)D Level | Vit D level CI/SE/SD* | Mean Ca intake or Ca balance | Ca CI/SE/SD* | P between groups
17521921 | Oken 2007 | Cases: preeclampsia | | adj for total energy intake only | 59 | | | 1270 mg | 443 | NS
| | Control: normal BP | | | 1540 | | | 1309 mg | 416

Duplicate one table per outcome

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
17521921 | Oken 2007 | preeclampsia | A multivariate logistic regression did not show an association between calcium (dietary and supplement) intake and preeclampsia (OR 1.03 per 300 mg of calcium; 95%CI 0.84–1.27).
| | gestational HTN | see table 2 in paper for results

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
17521921 | Oken 2007 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | N | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | N | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
17521921 | Oken 2007 | b) Sampling of population random or consecutive? (y/n) | nd | b) Outcome assessor blinded to exposure measurement? (y/n) | N | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | N | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | Y
17521921 | Oken 2007 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | did not calibrate the semi-quantitative FFQ for calcium

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Otani 2007

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17622244 | Otani 2007 | Case-cohort study | - Residents living in several municipalities administered by the Japan Public Health Center (Aged 40–59y for Cohort 1, Aged 40–69y for Cohort 2) (n=133323); - Subjects donated blood, returned the baseline questionnaire, without diagnosis of any cancer (n=38873); - Cases: adenocarcinoma including CIS; - Controls: 1:2 matching based on sex, age (<3 y), date of blood draw (<3 mo), time since last meal (<4 h), study location | - Cases: Non-adenocarcinoma or no pathological verification (n=25) | 1990 (Cohort 1) 1993 (Cohort 2) | The Japan Public Health Centre-based Prospective Study | Ministry of Health, Labour, and Welfare, Japan | JHL/TTe

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
17622244 | Otani 2007 | Case-cohort study | Japan (~ 30° –40° N) | Original cohort (N=133323), Subjects donated blood, returned the baseline questionnaire, without diagnosis of any cancer (N=38873), cases (N=375) and controls (N=750) | 1125 | Men 56.9 (no SD) Women 56.4 (no SD) | 40–69 | 52% | (Japanese or Asian ~100%) | BMI Men: 23.4 Women: 23.6 | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (e.g. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
17622244 | Otani 2007 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | Competitive protein-binding assay with Gc-Globulin modification | Intra-assay coefficient of variation (CV)=8.4% (n=9) | Inferring 9–14 y (cohort 2) or 12–17 y (cohort 1). (Collected in 1990–1992 for Cohort 1, and 1993–1995 for cohort 2. Last follow-up 12/2003) | nd | VitD intake (μg/d) Men: 6.6 Women: 5.3
17622244 | Otani 2007 | Dietary calcium intake | FFQ (Tsubono et al, 2003), 44 items (cohort 1) and 52 items (cohort 2) | nd | nd | | | | | Ca intake (mg/d) Men: 455.7 Women: 432.7

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17622244 | Otani 2007 | nd | Colorectal cancer | Adenocarcinoma (Collected for the JPHC cancer registry through local major hospitals, and population-based cancer registries) with pathological verification ~95%, death certificates only ~5%. ICD 180–189, 199, and 209
17622244 | Otani 2007 | nd | Colon cancer | See above (ICD180–189 only)
17622244 | Otani 2007 | nd | Rectal cancer | See above (ICD199 and 209 only)

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17622244 | Otani 2007 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Energy intake, vitamin supplement use | Matching factors: sex, age, date of blood draw, time since last meal, study location Further adjustment for n-3 polyunsaturated fatty acid or fish intake (results not materially changed [data not shown])
17622244 | Otani 2007 | Demographics (e.g., age, gender, race, education)? | Yes - age, gender
17622244 | Otani 2007 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes - BMI
17622244 | Otani 2007 | Medical conditions | Family Hx of colorectal cancer
17622244 | Otani 2007 | Medication
17622244 | Otani 2007 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | Physical exercise
17622244 | Otani 2007 | Smoking and other life styles variables | Yes - smoking, alcohol
17622244 | Otani 2007 | Other | Family history of colorectal cancer, cohort

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non-cases/Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
17622244 | Otani 2007 | Colorectal cancer | Men 25 (OH)vitaminD – lowest | <22.9 | | 43 | 74 | Adjusted | RR | 1.0 (ref) | | | 0.39
| | | Men 25 (OH)vitaminD – second | 22.9–27.5 | | 40 | 85 | Adjusted | | 0.76 | 0.42–1.4
| | | Men 25 (OH)vitaminD – third | 27.6–32.0 | | 36 | 85 | Adjusted | | 0.76 | 0.39–1.5
| | | Men 25 (OH)vitaminD highest | 32.1+ | | 44 | 80 | Adjusted | | 0.73 | 0.35–1.5
17622244 | Otani 2007 | Colorectal cancer | Women 25 (OH)vitaminD lowest | <22.9 | | 41 | 77 | Adjusted | RR | 1.0 (ref) | | | 0.74
| | | Women 25 (OH)vitaminD second | 22.9–27.5 | | 34 | 73 | Adjusted | | 1.0 | 0.55–1.9
| | | Women 25 (OH)vitaminD third | 27.6–32.0 | | 44 | 71 | Adjusted | | 1.2 | 0.65–2.3
| | | Women 25 (OH)vitaminD highest | 32.1+ | | 41 | 76 | Adjusted | | 1.1 | 0.50–2.3
17622244 | Otani 2007 | Colon cancer | Men 25 (OH)vitaminD lowest | <22.9 | | 25 | 54 | Adjusted | RR | 1.0 (ref) | | | 0.70
| | | Men 25 (OH)vitaminD second | 22.9–27.5 | | 27 | 55 | Adjusted | | 0.98 | 0.48–2.0
| | | Men 25 (OH)vitaminD third | 27.6–32.0 | | 29 | 66 | Adjusted | | 1.0 | 0.48–2.3
| | | Men 25 (OH)vitaminD highest | 32.1+ | | 38 | 62 | Adjusted | | 1.2 | 0.51–2.7
17622244 | Otani 2007 | Colon cancer | Women 25 (OH)vitaminD lowest | <22.9 | | 21 | 53 | Adjusted | RR | 1.0 (ref) | | | 0.12
| | | Women 25 (OH)vitaminD second | 22.9–27.5 | | 27 | 48 | Adjusted | | 1.7 | 0.78–3.6
| | | Women 25 (OH)vitaminD third | 27.6–32.0 | | 27 | 41 | Adjusted | | 2.1 | 0.90–4.7
| | | Women 25 (OH)vitaminD highest | 32.1+ | | 31 | 53 | Adjusted | | 2.1 | 0.78–5.6
17622244 | Otani 2007 | Rectal cancer | Men 25 (OH)vitaminD lowest | <22.9 | | 18 | 20 | Adjusted | RR | 1.0 (ref) | | | 0.06
| | | Men 25 (OH)vitaminD second | 22.9–27.5 | | 13 | 30 | Adjusted | | 0.17 | 0.024–1.2
| | | Men 25 (OH)vitaminD third | 27.6–32.0 | | 7 | 19 | Adjusted | | 0.25 | 0.051–1.3
| | | Men 25 (OH)vitaminD highest | 32.1+ | | 6 | 18 | Adjusted | | 0.075 | 0.0057–0.99
17622244 | Otani 2007 | Rectal cancer | Women 25 (OH)vitaminD lowest | <22.9 | | 20 | 24 | Adjusted | RR | 1.0 (ref) | | 0.22 | 0.17
| | | Women 25 (OH)vitaminD second | 22.9–27.5 | | 7 | 25 | Adjusted | | 0.26 | 0.069–1.0
| | | Women 25 (OH)vitaminD third | 27.6–32.0 | | 17 | 30 | Adjusted | | 0.46 | 0.15–1.4
| | | Women 25 (OH)vitaminD highest | 32.1+ | | 10 | 23 | Adjusted | | 0.33 | 0.084–1.3

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

MEAN DATA

THIS SHOULD ONLY APPLY TO CASE-COHORT STUDIES THAT COMPARE BASELINE VIT D/CA LEVELS BETWEEN CASES (WITH DISEASE) AND CONTROLS (WITHOUT DISEASE)

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Mean 25(OH)D Level | Vit D level CI/SE/SD* | Mean Ca intake or Ca balance | Ca CI/SE/SD* | P between groups
17622244 | Otani 2007 (colorectal) | Cases: Men | 10–13 y | Adjusted ** | 196 | 27.3 *** | 22.2–32.8 **** | | | 0.67
17622244 | Otani 2007 (colorectal) | Control: Men | 10–13 y | Adjusted ** | 392 | 27.6 *** | 22.9–32.1 ****
17622244 | Otani 2007 (colorectal) | Cases: Women | 10–13 y | Adjusted ** | 179 | 22.5 *** | 18.5–27.1 **** | | | 0.91
17622244 | Otani 2007 (colorectal) | Control: Women | 10–13 y | Adjusted ** | 358 | 22.3 *** | 18.7–27.0 ****
17622244 | Otani 2007 (colon) | Cases: Men | 10–13 y | Adjusted ** | 141 | 28.3 | 23.0–35.0 | | | 0.25
17622244 | Otani 2007 (colon) | Control: Men | 10–13 y | Adjusted ** | 282 | 28.0 | 23.0–32.3
17622244 | Otani 2007 (colon) | Cases: Women | 10–13 y | Adjusted ** | 115 | 23.3 | 19.1–27.3 | | | 0.25
17622244 | Otani 2007 (colon) | Control: Women | 10–13 y | Adjusted ** | 230 | 22.0 | 18.5–27.5
17622244 | Otani 2007 (rectal) | Cases: Men | 10–13 y | Adjusted ** | 55 | 24.3 | 20.2–29.1 | | | 0.0051
17622244 | Otani 2007 (rectal) | Control: Men | 10–13 y | Adjusted ** | 110 | 26.6 | 22.9–31.2
17622244 | Otani 2007 (rectal) | Cases: Women | 10–13 y | Adjusted ** | 64 | 20.6 | 17.8–25.3 | | | 0.093
17622244 | Otani 2007 (rectal) | Control: Women | 10–13 y | Adjusted ** | 128 | 22.6 | 19.1–26.5

Duplicate one table per outcome

** Tested by extensions of Mantel-Haenszel procedure with matched pairs.

*** median

**** interquartile range

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
17622244 | Otani 2007 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | Y | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | Y | a) Level of the exposure in comparative categories (e.g. quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
17622244 | Otani 2007 | b) Sampling of population random or consecutive? (y/n) | nd | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | nd | Time from sample collection to sample analysis reported? (y/n) | Y | a) Level of the exposure in comparative categories (e.g. quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
17622244 | Otani 2007 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | nd | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Some poor reporting, no internal calibration of FFQ

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

Comments

***During follow-up, 9.9% moved away, and 0.2% were lost.

## Park 2007a

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17215380 | Park 2007 | Cohort study | Adults aged 45–75 years from five targeted ethnic racial groups: African Americans, Native Hawaiians, Japanese Americans, Latinos, and Whites | Participants who are not in one of the targeted ethnic group or who reported implausible dietary intakes. Participants with previous colorectal cancer reported on the baseline questionnaire or identified from the cancer registries of Hawaii and California | 1993–1996 | Multiethnic Cohort Study | National Cancer Institute | JHL

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
17215380 | Park 2007 | Cohort study | Hawaii (21° N) Los Angeles, California (34° N) | 215,000 | 191,011 | nd | nd | 45% | African Americans, Native Hawaiians, Japanese Americans, Latinos, and Whites | nd | nd | Nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
17215380 | Park 2007 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | nd | nd | nd | VitD intake 335 IU (men) 340 IU (women)
17215380 | Park 2007 | Dietary calcium intake | Food frequency questionnaire | Data base developed at the cancer research center of Hawaii | Y, quantitative food frequency questionnaire, 3 repeated 24-hr recalls, correlations (Ca: 0.67, VitD: 0.61) | | | | | Ca 960mg (men) 1066mg (women)

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17215380 | Park 2007 | nd | Colorectal cancer | Identified by means of linkage of to the Surveillance, Epidemiology, End Results cancer registries covering Hawaii and California

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17215380 | Park 2007 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Total energy intake, dietary fiber intake
17215380 | Park 2007 | Demographics (e.g., age, gender, race, education)? | Yes - ethnicity, age
17215380 | Park 2007 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes - BMI,
17215380 | Park 2007 | Medical conditions
17215380 | Park 2007 | Medication | Use of nonsteroidal anti-inflammatory drugs, hormone replacement therapy (women); use of multivitamins
17215380 | Park 2007 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
17215380 | Park 2007 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes - smoking, family history of colorectal cancer, physical activity, history of intestinal polyps
17215380 | Park 2007 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non- cases/Total N ** | Follow up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
17215380 | Park 2007 | Colorectal cancer (Men) | Ca quintile 1 | | <288 mg/1000kcal/d | 342 | nd | 87.6 | Adjusted | RR | 1.00 | | | 0.006
| | | Ca quintile 2 | | 288 -< 369 mg/1000kcal/d | 271 | Nd | 87.6 | Adjusted | | 1.02 | 0.86–1.22
| | | Ca quintile 3 | | 369 -< 457 mg/1000kcal/d | 258 | Nd | 87.6 | Adjusted | | 1.08 | 0.89–1.31
| | | Ca quintile 4 | | 457 -< 611 mg/1000kcal/d | 177 | Nd | 87.6 | Adjusted | | 0.85 | 0.68–1.07
| | | Ca quintile 5 | | ≥ 611 mg/1000kcal/d | 90 | Nd | 87.6 | Adjusted | | 0.70 | 0.52–0.93
17215380 | Park 2007 | Colorectal cancer (Women) | Ca quintile 1 | | <288 mg/1000kcal/d | 172 | Nd | 87.6 | Adjusted | | 1.00 | | | 0.003
| | | Ca quintile 2 | | 288 -< 369 mg/1000kcal/d | 175 | nd | 87.6 | Adjusted | | 0.77 | 0.60–0.97
| | | Ca quintile 3 | | 369 -< 457 mg/1000kcal/d | 194 | Nd | 87.6 | Adjusted | | 0.76 | 0.60–0.97
| | | Ca quintile 4 | | 457 -< 611 mg/1000kcal/d | 197 | Nd | 87.6 | Adjusted | | 0.74 | 0.57–0.94
| | | Ca quintile 5 | | ≥ 611 mg/1000kcal/d | 234 | Nd | 87.6 | Adjusted | | 0.64 | 0.50–0.83

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

**** Models were also included intakes from food, supplements and foods excluding users of multivitamin or calcium supplements for data analysis.

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | No. of Non- cases/Total N** | Follow up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups*** | P for trend****
17215380 | Park 2007 | Colorectal cancer (African Americans) | Ca quintile 1 | | <309 mg/1000kcal/d | 126 | nd | 87.6 | Adjusted | RR | 1.00 | | | 0.18
| | | Ca quintile 2 | | 309–< 410 mg/1000kcal/d | 121 | Nd | 87.6 | Adjusted | | 0.77 | 0.58–1.03
| | | Ca quintile 3 | | 410–< 558 mg/1000kcal/d | 133 | Nd | 87.6 | Adjusted | | 1.03 | 0.77–1.40
| | | Ca quintile 4 | | ≥558 mg/1000kcal/d | 67 | Nd | 87.6 | Adjusted | | 0.70 | 0.48–1.02
17215380 | Park 2007 | Colorectal cancer (Native Hawaiians) | Ca quintile 1 | | <309 mg/1000kcal/d | 69 | Nd | 87.6 | Adjusted | RR | 1.00 | | | 0.08
| | | Ca quintile 2 | | 309–< 410 mg/1000kcal/d | 33 | Nd | 87.6 | Adjusted | | 0.69 | 0.43–1.12
| | | Ca quintile 3 | | 410–< 558 mg/1000kcal/d | 28 | Nd | 87.6 | Adjusted | | 0.93 | 0.54–1.58
| | | Ca quintile 4 | | ≥558 mg/1000kcal/d | 11 | Nd | 87.6 | Adjusted | | 0.44 | 0.20–0.99
17215380 | Park 2007 | Colorectal cancer (Japanese Americans) | Ca quintile 1 | | <309 mg/1000kcal/d | 312 | Nd | 87.6 | Adjusted | RR | 1.00 | | | 0.008
| | | Ca quintile 2 | | 309–< 410 mg/1000kcal/d | 177 | Nd | 87.6 | Adjusted | | 0.99 | 0.80–1.22
| | | Ca quintile 3 | | 410–< 558 mg/1000kcal/d | 125 | Nd | 87.6 | Adjusted | | 0.85 | 0.66–1.10
| | | Ca quintile 4 | | ≥558 mg/1000kcal/d | 117 | Nd | 87.6 | Adjusted | | 0.69 | 0.52–0.91
17215380 | Park 2007 | Colorectal cancer (Latinos) | Ca quintile 1 | | <309 mg/1000kcal/d | 45 | Nd | 87.6 | Adjusted | RR | 1.00 | | | 0.12
| | | Ca quintile 2 | | 309–< 410 mg/1000kcal/d | 122 | Nd | 87.6 | Adjusted | | 1.12 | 0.77–1.62
| | | Ca quintile 3 | | 410–< 558 mg/1000kcal/d | 117 | Nd | 87.6 | Adjusted | | 0.85 | 0.58–1.26
| | | Ca quintile 4 | | ≥558 mg/1000kcal/d | 81 | Nd | 87.6 | Adjusted | | 0.79 | 0.51–1.08
17215380 | Park 2007 | Colorectal cancer (Whites) | Ca quintile 1 | | <309 mg/1000kcal/d | 89 | Nd | 87.6 | Adjusted | RR | 1.00 | | | 0.04
| | | Ca quintile 2 | | 309–< 410 mg/1000kcal/d | 89 | Nd | 87.6 | Adjusted | | 0.73 | 0.54–1.01
| | | Ca quintile 3 | | 410–< 558 mg/1000kcal/d | 126 | Nd | 87.6 | Adjusted | | 0.81 | 0.60–1.11
| | | Ca quintile 4 | | ≥558 mg/1000kcal/d | 122 | Nd | 87.6 | Adjusted | | 0.65 | 0.46–0.91

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
17215380 | Park 2007 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | N | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | N | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | | Y
17215380 | Park 2007 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | N | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | | Y
17215380 | Park 2007 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Y | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | N | c) Justification of sample size (includes sample size calculations)? (y/n) | | N
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Power calculation not reported; blinding assessor not reported; cancer cases not confirmed by histology reports; study designed to assess relationship of diet with several cancer sites not specifically between calcium and CRC

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Park 2007b

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
18000020 | Park 2007 | Cohort study | AARP members (50–71); satisfactory dietary data | questionnaires completed by proxy; cancer before baseline (except for nonmelanoma skin cancer); self-reported ESRD; extreme total energy and calcium (food) intakes (>2x IQR of log-transformed intake) | 1995–1996 | (NIH)-AARP Diet & Health Study | NCI | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
18000020 | Park 2007 | Cohort study | CA, FL, LA, NJ, NC, PA | 339671 | 293888 | nd | 50–71 | 100 | 92% white (est.) | BMI 27.2 (est.) | nd | calcium from non-dairy food (346–370 mg/d); dairy calcium (211–997 mg/d); supplemental calcium (34–514 mg/d)

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | | | | nd
18000020 | Park 2007 | Dietary calcium intake | 124 item FFQ past 12 mo | USDA | FFQ validated by two 24 h recalls in 1953 participants; correlation with reference method was 0.63 | | | | | calcium from non- dairy food (346–370 mg/d); dairy calcium (211–997 mg/d); supplemental calcium (34–514 mg/d)

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
18000020 | Park 2007 | primary | incident prostate cancer | 8 state cancer registry databases; SSA Death Master File; Natl Death Index Plus

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
18000020 | Park 2007 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes | tomato, red meat, fish, vit E, α-linolenic acid, total energy intake, vit D
18000020 | Park 2007 | Demographics (e.g., age, gender, race, education)? | Yes | age; race; education
18000020 | Park 2007 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI
18000020 | Park 2007 | Medical conditions | Yes | DM; PSA screen
18000020 | Park 2007 | Medication
18000020 | Park 2007 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
18000020 | Park 2007 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | physical activity; smoking; alcohol
18000020 | Park 2007 | Other | Yes | marital status; FH prostate cancer

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non- cases/Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
18000020 | Park 2007 | total prostate cancer | total calcium intake (diet + supplement) | | <500 mg/d | 767 | | adj | RR | 1.01 | 0.93–1.10 | | 0.41
| | | | | 500 to <750 | 2927 | | | | 1.00
| | | | | 750 to <1000 | 2808 | | | | 0.99 | 0.93–1.04
| | | | | 1000 to <1500 | 2572 | | | | 0.99 | 0.93–1.05
| | | | | 1500 to <2000 | 797 | | | | 0.96 | 0.88–1.05
| | | | | ≥2000 | 309 | | | | 0.97 | 0.85–1.10
18000020 | Park 2007 | fatal prostate cancer | total calcium intake (diet + supplement) | | <500 mg/d | 11 | | adj | RR | 0.76 | 0.38–1.53 | | 0.99
| | | | | 500 to <750 | 43 | | | | 1.00
| | | | | 750 to <1000 | 56 | | | | 1.50 | 0.97–2.32
| | | | | 1000 to <1500 | 50 | | | | 1.42 | 0.86–2.35
| | | | | 1500 to <2000 | 18 | | | | 1.05 | 0.54–2.05
| | | | | ≥2000 | - | | | | - | -

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
18000020 | Park 2007 | nonadvanced and advanced prostate cancer | see Table 2 in paper

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
18000020 | Park 2007 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | N | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) Time from | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) b) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
| | b) Sampling of population random or consecutive? (y/n) | nd | b) Outcome assessor blinded to exposure measurement? (y/n) | N | b) Food composition database or suppl composition reported? (y/n) | Y | sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) b) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) c) | Y
| | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Y | | | | | Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | Y | Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | A
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | excluded 14,495 questionnaires filled out by proxies

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Park 2007c

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17925283 | Park 2007 | Cohort study | Male adults aged 45–75 years from five racial and ethnic populations living in California and Hawaii: African Americans, Native Hawaiians, Japanese Americans, Latinos, and Whites | Not in one of the specified ethnic groups or reporting implausible dietary intakes. Participants with prior prostate cancer occurrence through questionnaire or registry data. Men missing information on height, weight, education level, or smoking. | 1993–1996 | Multiethnic Cohort Study | National Cancer Institute | KP/SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake...etc.)
17925283 | Park 2007 | Cohort study | Hawaii (20° N) and California (32.30°–42° N) | Original cohort of 215,000 men and women, including 96,958 men | 82,483 | Nd | 45–75 | 100% | African Americans, Native Hawaiians, Japanese Americans, Latinos, and Whites | Nd | Nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
17925283 | Park 2007 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | NA | NA | NA | NA | ND
| | Dietary calcium intake | Self- administered quantitative FFQ | Food composition table developed by Cancer Research Center of Hawaii for use in Multiethnic Cohort Study | Y: calibration study comparing to 24-hr recall showed correlations of 0.67 and 0.61 respectively for calcium and vitamin D respectively. | | | | | 7% took calcium supplements regularly

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17925283 | Park 2007 | nd | Prostate cancer | Identified by linkage of cohort to SEER registry, state death files, National Death Index file. Includes all prostate cancers except in situ tumors.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17925283 | Park 2007 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Energy intake
17925283 | Park 2007 | Demographics (e.g., age, gender, race, education)? | Yes | Ethnicity, education
17925283 | Park 2007 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI
17925283 | Park 2007 | Medical conditions | Family history of prostate cancer
17925283 | Park 2007 | Medication
17925283 | Park 2007 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
17925283 | Park 2007 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | Smoking
17925283 | Park 2007 | Other | Time since cohort entry

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non- cases/Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups *** | P for trend ****
17925283 | Park 2007 | Prostate cancer | Total calcium <470 mg | nd | Nd | 706 | Nd | adjusted | RR | 1.00 | Reference | Nd | 0.69
| | | Total calcium 470–<692 mg | Nd | Nd | 925 | Nd | | | 1.03 | 0.93–1.15 | Nd
| | | Total calcium 692–<935 mg | Nd | Nd | 949 | Nd | | | 1.04 | 0.93–1.17 | Nd
| | | Total calcium 935–<1,300 mg | Nd | Nd | 936 | Nd | | | 1.05 | 0.93–1.18 | Nd
| | | Total calcium ≥1,301 mg | nd | Nd | 888 | nd | | | 1.04 | 0.91–1.20 | Nd
17925283 | Park 2007 | Prostate cancer | Total vit D <66 IU | nd | Nd | 639 | Nd | adjusted | RR | 1.00 | Reference | Nd | 0.64
| | | 66–<136 IU | Nd | Nd | 938 | Nd | | | 1.15 | 1.03–1.28 | Nd
| | | 136–<256 IU | Nd | Nd | 910 | Nd | | | 1.06 | 0.95–1.19 | Nd
| | | 256–<521 IU | Nd | Nd | 940 | Nd | | | 1.11 | 1.00–1.24 | Nd
| | | ≥521 IU | nd | Nd | 977 | nd | | | 1.09 | 0.98-1.22 | Nd

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary * assessment | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
17925283 | Park 2007 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | Y | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
17925283 | Park 2007 | b) Sampling of population random or consecutive? (y/n) | NA | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | NA | b) Analysis was planned when cohort was formed? (y/n) | nd
17925283 | Park 2007 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Y | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | N | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Incident cases ascertained through registries, unclear if they were verified. Solid dietary assessment description; sample size calculations and explanation for if analysis was pre-planned not reported.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Park 2009

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
19237724 | Park 2009 | Cohort study | - AARP members in 6 specific states and 2 specific metropolitan area, age 50 to 71 (n=?); - Participants who returned questionnaires (n=567,169) **** | GENERAL *****; - Provided duplicate questionnaires (n=179); - Requested to be withdrawn (n=6); - Had moved out of the study area or died before baseline (n=582); - Proxies for the intended respondents (n=15,760); - Any prevalent cancer except non-melanoma skin cancer at baseline (n=51,193); - End-stage renal disease at baseline (n=997); - Extreme *** intakes of total energy (n=4417); - Extreme *** intakes of total calcium (n=1225) OVARIAN CANCER ONLY (in addition to GENERAL); - History of oophorectomy (n=43,536) ENDOMETRIAL CANCER ONLY (in addition to GENERAL); - History of hysterectomy (n=81,025) | 1995–1996 | NIH-AARP Diet and Health Study (NIH-AARP = National Institutes of Health-American Association of Retired Persons) | NIH (US) | TTe

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

*** Extreme was defined as “greater than twice the interquartile ranges above the 75th percentile or below the 25th percentile of sex-specific log-transformed intake”

**** Unclear how many is the total number of AARP members (=denominator of this number to estimate a response rate)

***** At least 13% of questionnaire responders excluded for some reason.

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
19237724 | Park 2009 | Cohort study | California, Florida, Louisiana, New Jersey, and North Carolina (6 states), and Pennsylvania, Atlanta, Georgia, Detroit, and Michigan (2 metropolitan regions) | N=492,810 (M=293,907, F=198,903) | N=492,810 (M=293,907, F=198,903) | nd | 50-71 (range) | 60% | White (non- Hispanic): M= ~92% F= ~89% | BMI: M= ~27.2 F= ~26.7 | Family history of any cancer: M= ~47% F= ~51% Current smoker: M= ~12% F= ~15% Antacid user: M=~31% F= ~30% Hormone replacement therapy user: F= ~40% | Ca-containing multivitamin user: M=49%, F=57% Ca supplement user (only 4 or more times/week): M=14%, F=41%

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed information as possible on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
19237724 | Park 2009 | Dietary calcium intake | FFQ (NCI-DHQ) | USDA 1994–1996 | Yes (in 1953 participants against 2 non-consecutive 24- hour dietary recalls) ***** The energy-adjusted correlation coefficient of dietary Ca intake and the reference method: M (0.63), F (0.64) | nd | | | | Total calcium intake (10 ^ th ^ to 90 ^ th ^ percentile): M=526 to 1530 mg/d, F=494 to 1881 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

***** Not explicitly mentioned how they were extracted or if they were representative of the included cohort.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
19237724 | Park 2009 | Nd *** | All cancers | Identified thorough a cancer registry database from 11 states by ICD codes (3 ^ rd ^ edition). Previous study showed that approximately 90% of cases were identified within 2years of cancer occurrence **** .
| | Nd *** | Head and neck cancer | The same as all cancer
| | Nd *** | Esophageal cancer | The same as all cancer
| | Nd *** | Stomach cancer | The same as all cancer
| | Nd *** | Colorectal cancer | The same as all cancer
| | Nd *** | Liver cancer | The same as all cancer
| | Nd *** | Pancreatic cancer | The same as all cancer
| | Nd *** | Lung cancer | The same as all cancer
| | Nd *** | Breast cancer | The same as all cancer
| | Nd *** | Ovarian cancer | The same as all cancer
| | Nd *** | Endometrial cancer | The same as all cancer
| | Nd *** | Bladder cancer | The same as all cancer
| | Nd *** | Kidney cancer | The same as all cancer
| | Nd *** | Thyroid cancer | The same as all cancer
| | Nd *** | Brain cancer | The same as all cancer
| | Nd *** | Non-Hodgkin lymphoma (NHL) | Identified through “Surveillance Epidemiology and End Results Program”
| | Nd *** | Leukemia | The same as NHL
| | Nd *** | Myeloma | The same as NHL
| | Nd *** | “Digestive system” | A combined category. See the foot note ***** below.
| | Nd *** | “Respiratory system” (excluding larynx) | A combined category. See the foot note ***** below.
| | Nd *** | “Reproductive system” | A combined category. See the foot note ***** below.
| | Nd *** | “Women” | A combined category. See the foot note ***** below.
| | Nd *** | “Urinary system” | A combined category. See the foot note ***** below.
| | Nd *** | “Brain and other nervous system” | A combined category. See the foot note ***** below.
| | Nd *** | “Endocrine system” | A combined category. See the foot note ***** below.
| | Nd *** | “Others” | A combined category excluding above categories (not explicitly stated)

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

*** Twenty-six outcomes reported without explicit description of “what is the primary outcome of interest”

**** Head and neck (C000–C009, C019–C119, C129–C140, C142–C148, C300–C301, C310–C329, C339–C349, C381–C384, C388, C390, C398, and C399), esophageal (C150–C159), stomach (C160–C169), colorectal (C180–C189, C199, C209, and C260), liver (C220 and C221), pancreatic (C250–C259), lung (C340–C349), breast (C500–C509), ovarian (C569), endometrial (C540–C549 and C559), prostate (C619), bladder (C670–C679), kidney (C649 and C659), thyroid (C739), and brain (C710–C719) cancer.

***** Digestive system (C150–C189, C199, C209–C212, C218, C220–C221, C239–C260, C268–C269, C480–C482, and C488); respiratory system, excluding larynx (C300–C301, C310–C319, C339–C349, C381–C384, C388, C390, C398, and C399); reproductive system (men: C600–C609, C619–C639; women: C510–C519, C529–C549, C559, and C569–C589); urinary system (C649, C659, and C669–C689); brain and other nervous systems (C700–C729); endocrine system (C739–C759, and C379)

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
19237724 | Park 2009 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes (intake of fruits and vegetables, red meat, whole grains, tomatoes, total fat, protein, folate, linoleic acid, selenium, and total energy
19237724 | Park 2009 | Demographics (e.g., age, gender, race, education)? | Yes (race/ethnicity, education
19237724 | Park 2009 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes (body mass index
19237724 | Park 2009 | Medical conditions | Yes (family history of cancer, history of hypertension and diabetes, PSA test in men, age at menopause; and history of oophorectomy and hysterectomy in women)
19237724 | Park 2009 | Medication | Yes (antacid use, menopausal hormone therapy and duration, parity; oral contraceptive use
19237724 | Park 2009 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | No
19237724 | Park 2009 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes (vigorous physical activity, smoking status; time since quitting smoking; smoking dose, consumptionof alcohol and total beverages
19237724 | Park 2009 | Other | marital status

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Median total Ca intake (mg/d) | No. of Cases (Event) * | No. of Non- cases/Total N ** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
Men
19237724 | Park 2009 | All cancers (N=36965) | Q1 | | 526 | | | 84 | Adj | HR | 1 | Ref | | 0.74
| | | Q2 | | 498 | | | 84 | Adj | HR | 0.99 | 0.96–1.03
| | | Q3 | | 857 | | | 84 | Adj | HR | 0.99 | 0.96–1.03
| | | Q4 | | 1073 | | | 84 | Adj | HR | 0.95 | 0.96–1.03
| | | Q5 | | 1530 | | | 84 | Adj | HR | 0.99 | 0.95–1.03
19237724 | Park 2009 | Colorectal cancer (n=3463) | Q1 | | 526 | | | 84 | Adj | HR | 1 | Ref | | 0.001
| | | Q2 | | 498 | | | 84 | Adj | HR | 0.89 | 0.80–0.98
| | | Q3 | | 857 | | | 84 | Adj | HR | 0.83 | 0.75–0.93
| | | Q4 | | 1073 | | | 84 | Adj | HR | 0.87 | 0.78–0.97
| | | Q5 | | 1530 | | | 84 | Adj | HR | 0.79 | 0.70–0.89
19237724 | Park 2009 | Pancreatic cancer (n=717) | Q1 | | 526 | | | 84 | Adj | HR | 1 | Ref | | 0.39
| | | Q2 | | 498 | | | 84 | Adj | HR | 0.93 | (0.74–1.16)
| | | Q3 | | 857 | | | 84 | Adj | HR | 0.9 | (0.72–1.14)
| | | Q4 | | 1073 | | | 84 | Adj | HR | 0.98 | (0.78–1.23)
| | | Q5 | | 1530 | | | 84 | Adj | HR | 0.87 | (0.68–.11)
19237724 | Park 2009 | Prostate cancer (n=17 189) | Q1 | | 526 | | | 84 | Adj | HR | 1 | ref | | 0.21
| | | Q2 | | 498 | | | 84 | Adj | HR | 0.99 | (0.95–1.04)
| | | Q3 | | 857 | | | 84 | Adj | HR | 1.01 | (0.96–1.06)
| | | Q4 | | 1073 | | | 84 | Adj | HR | 1 | (0.95–1.05)
| | | Q5 | | 1530 | | | 84 | Adj | HR | 1.03 | (0.98–1.08)
Women
19237724 | Park 2009 | All cancers (N=16605) | Q1 | | 494 | | | 84 | Adj | HR | 1 | Ref | | 0.23
| | | Q2 | | 717 | | | 84 | Adj | HR | 0.98 | 0.93–1.03
| | | Q3 | | 969 | | | 84 | Adj | HR | 0.94 | 0.89–0.99
| | | Q4 | | 1296 | | | 84 | Adj | HR | 0.93 | 0.88–0.98
| | | Q5 | | 1881 | | | 84 | Adj | HR | 0.96 | 0.91–1.02
19237724 | Park 2009 | Colorectal cancer (n=1635) | Q1 | | 494 | | | 84 | Adj | HR | 1 | Ref | | 0.001
| | | Q2 | | 717 | | | 84 | Adj | HR | 0.87 | 0.75–1.01
| | | Q3 | | 969 | | | 84 | Adj | HR | 0.83 | 0.71–0.97
| | | Q4 | | 1296 | | | 84 | Adj | HR | 0.71 | 0.60–0.84
| | | Q5 | | 1881 | | | 84 | Adj | HR | 0.72 | 0.61–0.86
19237724 | Park 2009 | Pancreatic cancer (n=384) | Q1 | | 494 | | | 84 | Adj | HR | 1 | Ref | | 0.4
| | | Q2 | | 717 | | | 84 | Adj | HR | 1.03 | 0.75–1.40
| | | Q3 | | 969 | | | 84 | Adj | HR | 0.93 | 0.67–1.28
| | | Q4 | | 1296 | | | 84 | Adj | HR | 0.97 | 0.71–1.34
| | | Q5 | | 1881 | | | 84 | Adj | HR | 0.88 | 0.63–1.24
19237724 | Park 2009 | Breast cancer (n=5856) | Q1 | | 494 | | | 84 | Adj | HR | 1 | Ref | | 0.84
| | | Q2 | | 717 | | | 84 | Adj | HR | 0.96 | 0.88–1.04
| | | Q3 | | 969 | | | 84 | Adj | HR | 0.95 | 0.87–1.03
| | | Q4 | | 1296 | | | 84 | Adj | HR | 0.94 | 0.86–1.02
| | | Q5 | | 1881 | | | 84 | Adj | HR | 0.98 | 0.90–1.07

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
19237724 | Park 2009 | All the presented outcomes:
19237724 | Park 2009 | Men
19237724 | Park 2009 | Cancer category | Q1 | CI | Q2 | CI | Q3 | CI | Q4 | CI | Q5 | CI | p for trend
19237724 | Park 2009 | All cancers (N=36965) | 1 | [Reference] | 0.99 | (0.96– 1.03) | 0.99 | (0.96– 1.03) | 0.95 | (0.96– 1.03) | 0.99 | (0.95– 1.03) | 0.74
19237724 | Park 2009 | Head and neck cancer (n=1038) | 1 | [Reference] | 1 | (0.83– 1.20) | 0.9 | (0.74– 1.10) | 0.99 | (0.82– 1.21) | 0.99 | (0.81– 1.21) | 0.99
19237724 | Park 2009 | Esophageal cancer (n=468) | 1 | [Reference] | 0.98 | (0.74– 1.29) | 0.84 | (0.63– 1.13) | 0.89 | (0.67– 1.19) | 0.84 | (0.62– 1.13) | 0.23
19237724 | Park 2009 | Stomach cancer (n=512) | 1 | [Reference] | 1.07 | (0.81– 1.41) | 1.13 | (0.86– 1.48) | 1.04 | (0.79– 1.38) | 0.96 | (0.72– 1.29) | 0.58
19237724 | Park 2009 | Colorectal cancer (n=3463) | 1 | [Reference] | 0.89 | (0.80– 0.98) | 0.83 | (0.75– 0.93) | 0.87 | (0.78– 0.97) | 0.79 | (0.70– 0.89) | 0.001
19237724 | Park 2009 | Liver cancer (n=311) | 1 | [Reference] | 0.75 | (0.52– 1.08) | 1.2 | (0.87– 1.67) | 0.83 | (0.58– 1.20) | 0.88 | (0.61– 1.27) | 0.61
19237724 | Park 2009 | Pancreatic cancer (n=717) | 1 | [Reference] | 0.93 | (0.74– 1.16) | 0.9 | (0.72– 1.14) | 0.98 | (0.78– 1.23) | 0.87 | (0.68– 1.11) | 0.39
19237724 | Park 2009 | Lung cancer (n=4287) | 1 | [Reference] | 1.05 | (0.96– 1.15) | 1.03 | (0.94– 1.13) | 1.03 | (0.94– 1.13) | 1.03 | (0.93– 1.13) | 0.76
19237724 | Park 2009 | Prostate cancer (n=17189) | 1 | [Reference] | 0.99 | (0.95– 1.04) | 1.01 | (0.96– 1.06) | 1 | (0.95– 1.05) | 1.03 | (0.98– 1.08) | 0.21
19237724 | Park 2009 | Prostate cancer excluding non– aggressive cases (n=nd) | 1 | {Reference} | 1.00 | nd | 0.98 | nd | 0.99 | nd | 0.96 | (0.92– 1.02) | 0.16
19237724 | Park 2009 | Bladder cancer (n=1417) | 1 | [Reference] | 0.96 | (0.82– 1.13) | 0.82 | (0.69– 0.97) | 0.87 | (0.73– 1.03) | 0.87 | (0.73– 1.03) | 0.11
19237724 | Park 2009 | Kidney cancer (n=991) | 1 | [Reference] | 0.9 | (0.74– 1.10) | 0.93 | (0.76– 1.14) | 0.94 | (0.76– 1.15) | 0.8 | (0.64– 1.01) | 0.1
19237724 | Park 2009 | Thyroid cancer (n=170) | 1 | [Reference] | 0.95 | (0.58– 1.56) | 1.07 | (0.66– 1.74) | 1.15 | (0.71– 1.87) | 0.79 | (0.46– 1.34) | 0.43
19237724 | Park 2009 | Brain cancer (n=390) | 1 | [Reference] | 0.79 | (0.57– 1.10) | 0.82 | (0.59– 1.13) | 0.91 | (0.66– 1.25) | 0.89 | (0.65– 1.23) | 0.98
19237724 | Park 2009 | Non-Hodgkin lymphoma (n=1267) | 1 | [Reference] | 1.03 | (0.86– 1.24) | 1.15 | (0.96– 1.38) | 0.95 | (0.79– 1.14) | 1.02 | (0.85– 1.23) | 0.77
19237724 | Park 2009 | Leukemia (n=757) | 1 | [Reference] | 0.93 | (0.74– 1.17) | 0.95 | (0.75– 1.19) | 0.96 | (0.76– 1.21) | 0.88 | (0.69– 1.21) | 0.38
19237724 | Park 2009 | Myeloma (n=369) | 1 | [Reference] | 1.03 | (0.74– 1.43) | 1.07 | (0.77– 1.48) | 0.91 | (0.65– 1.28) | 0.92 | (0.65– 1.30) | 0.42
19237724 | Park 2009 | “Digestive system cancer” multivariate HR (Q5 vs Q1) = 0.84 (95%CI, 0.77–0.92); No associations between total Ca intake and other anatomical system cancers
19237724 | Park 2009 | Women
19237724 | Park 2009 | Cancer category | Q1 | CI | Q2 | CI | Q3 | CI | Q4 | CI | Q5 | CI | p for trend
19237724 | Park 2009 | All cancers (N=16605) | 1 | [Reference] | 0.98 | (0.93– 1.03) | 0.94 | (0.89– 0.99) | 0.93 | (0.88– 0.98) | 0.96 | (0.91– 1.02) | 0.23
19237724 | Park 2009 | Head and neck cancer (n=325) | 1 | [Reference] | 1.33 | (0.97– 1.83) | 0.92 | (0.64– 1.31) | 1.02 | (0.71– 1.46) | 1.3 | (0.91– 1.86) | 0.42
19237724 | Park 2009 | Esophageal cancer (n=79) | 1 | [Reference] | 1.47 | (0.80– 2.71) | 1.14 | (0.59– 2.22) | 0.56 | (0.24– 1.31) | 0.83 | (0.38– 1.81) | 0.18
19237724 | Park 2009 | Stomach cancer (n=143) | 1 | [Reference] | 0.9 | (0.54– 1.50) | 1.37 | (0.85– 2.20) | 0.55 | (0.30– 1.01) | 0.71 | (0.40– 1.25) | 0.08
19237724 | Park 2009 | Colorectal cancer (n=1635) | 1 | [Reference] | 0.87 | (0.75– 1.01) | 0.83 | (0.71– 0.97) | 0.71 | (0.60– 0.84) | 0.72 | (0.61– 0.86) | 0.001
19237724 | Park 2009 | Liver cancer (n=86) | 1 | [Reference] | 1.38 | (0.73– 2.61) | 1.1 | (0.55– 2.17) | 1.05 | (0.52– 2.13) | 0.96 | (0.46– 2.03) | 0.6
19237724 | Park 2009 | Pancreatic cancer (n=384) | 1 | [Reference] | 1.03 | (0.75– 1.40) | 0.93 | (0.67– 1.28) | 0.97 | (0.71– 1.34) | 0.88 | (0.63– 1.24) | 0.4
19237724 | Park 2009 | Lung cancer (n=2457) | 1 | [Reference] | 0.96 | (0.85– 1.08) | 0.91 | (0.81– 1.03) | 0.94 | (0.83– 1.07) | 1 | (0.88– 1.14) | 0.95
19237724 | Park 2009 | Breast cancer (n=5856) | 1 | [Reference] | 0.96 | (0.88– 1.04) | 0.95 | (0.87– 1.03) | 0.94 | (0.86– 1.02) | 0.98 | (0.90– 1.07) | 0.84
19237724 | Park 2009 | Ovarian cancer (n=515) | 1 | [Reference] | 1.04 | (0.78– 1.38) | 0.99 | (0.74– 1.33) | 1.05 | (0.79– 1.41) | 1.14 | (0.85– 1.52) | 0.34
19237724 | Park 2009 | Endometrial cancer (n=1171) | 1 | [Reference] | 1.11 | (0.92– 1.33) | 1.01 | (0.84– 1.22) | 1.1 | (0.91– 1.32) | 0.99 | (0.81– 1.20) | 0.66
19237724 | Park 2009 | Bladder cancer (n=264) | 1 | [Reference] | 0.97 | (0.67– 1.41) | 0.94 | (0.64– 1.37) | 0.91 | (0.61– 1.35) | 0.97 | (0.65– 1.46) | 0.85
19237724 | Park 2009 | Kidney cancer (n=367) | 1 | [Reference] | 0.87 | (0.63– 1.21) | 0.81 | (0.58–1.13) | 0.73 | (0.51–1.03) | 0.79 | (0.55–1.13) | 0.21
19237724 | Park 2009 | Thyroid cancer (n=199) | 1 | [Reference] | 0.98 | (0.63– 1.54) | 1.07 | (0.69– 1.67) | 0.88 | (0.55– 1.41) | 1.04 | (0.65– 1.65) | 0.98
19237724 | Park 2009 | Brain cancer (n=160) | 1 | [Reference] | 0.94 | (0.59– 1.50) | 0.7 | (0.42– 1.16) | 0.79 | (0.48– 1.29) | 0.72 | (0.43– 1.21) | 0.2
19237724 | Park 2009 | Non-Hodgkin lymphoma (n=660) | 1 | [Reference] | 0.96 | (0.75– 1.23) | 0.89 | (0.69– 1.15) | 0.99 | (0.77– 1.28) | 1.24 | (0.97– 1.59) | 0.03
19237724 | Park 2009 | Leukemia (n=280) | 1 | [Reference] | 0.92 | (0.63– 1.35) | 1 | (0.68– 1.46) | 0.92 | (0.62– 1.36) | 1.25 | (0.86– 1.83) | 0.17
19237724 | Park 2009 | Myeloma (n=175) | 1 | [Reference] | 1.33 | (0.79– 2.24) | 1.54 | (0.93– 2.57) | 1.91 | (1.16– 3.15) | 1.36 | (0.79– 2.36) | 0.25
19237724 | Park 2009 | “Digestive system cancer” multivariate HR (Q5 vs Q1) = 0.77 (95%CI, 0.69–0.91); No associations between total Ca intake and other anatomical system cancers
19237724 | Park 2009 | (Excerpt from the paper) In nonparametric regression analyses, the HRs for total cancer incidence in women decreased up to approximately 1300 mg/d of total Ca intake, and no further reduction was observed above 1300 mg/d (Fig 1)

Subgroup Analyses

NO data available stratified by age, or other categories of interest

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
19237724 | Park 2009 | a) Eligibility criteria clear? (y/n) | N | a) Exposure assessor blinded to outcome info? (y/n) | Nd | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | a) Clear definition of outcome, including time of ascertainment? (y/n) | y | a) Prospective collection of data? (y/n) | y
19237724 | Park 2009 | b) Sampling of population random or consecutive? (y/n) | nd | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | b) Loss to follow-up <20%? (y/n) | nd | b) Analysis was planned when cohort was formed? (y/n) | Nd
19237724 | Park 2009 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | y | | | | | b) Justification of final adjusted model selection? (y/n) | n | c) Do the authors specify a primary outcome? (y/n) | n | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Many eligible members might have been excluded, no blinded assessment of exposure and outcomes, and multiple outcomes collected and assessed without an explicitly stated analyses plan. No independent verification of the cases, only registry dependent data.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Pfeifer 2001

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
11297596 | Pfeifer 2001 | RCT | 25(OH)D < 50 nmol/L | -Hypercalcemia or 1 hyperparathyroidism - fractures of extremities due to osteoporosis -therapy w/thiazide, bisphosphonate, calcitonin, vit D3 and other vit D metabolites, estrogen, antiestrogen in the previous 6 months -therapy w/fluoride in previous 2 yrs. -known intolerance to study meds -chronic renal failure -hx of drug or EtOH abuse -nicotine abuse - > 7 cups coffee daily -scheduled holiday along the geographic longitude during the study period - DM - severe CVD - severe HTN (SBP>180 mm Hg, DBP >95 mm Hg | 1997 | - | Strathmann, Inc., which markets vit D and Ca, provided the supplements and funding for the study. | MB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
11297596 | Pfeifer 2001 | RCT | Lower Saxony, Germany 52 N | 148 | 145 | 75 ± 4 yrs. | Age range = 70 – 86 yrs. | 0% | nd | Mean weight = 65 kg. Mean height = 162 cm. | nd | 25(OH)D < 50 nmol/L

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
11297596 | Pfeifer 2001 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | 25(OH)D and 1,25(OH)D via RIA | Coeffs of variation for ALL assays ranged from 5.5 – 7.9% | nd | | Serum 25(OH)D = 25 ± 13 nmol/mL. Serum 1,25(OH)D = 36.5 ± 16 ng/L.
| | Dietary calcium intake | nd | nd | | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
11297596 | Pfeifer 2001 | Vit D + calcium | Ca carbonate Vit D3 | 1200 mg elemental Ca and 800 IU vit D3 | 8 wks | Capsules were taken 2x/day (breakfast and dinner with a meal)
| | Calcium | Ca carbonate | 1200 mg elemental Ca | 8 wks | Capsules were taken 2x/day (breakfast and dinner with a meal)
Co-intervention(s) * :
Compliance/adherence: | | | Assessed by pill counts, 95±12% for the Ca tablets and 96±10% for the Vit D3+Ca tablets, one subject in Ca group excluded for non-compliance

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
11297596 | Pfeifer 2001 | 1° | SBP | Measured after at least 5 min of supine rest using a sphygmomanometer. Systolic and diastolic blood pressures were taken at Korotkov sounds I and V.
| | 1° | DBP | Same as SBP
| | | 25(OH)D

UI | Author Year | Comments
11297596 | Pfeifer 2001 | 32 (47%) of the subjects in the Ca group and 36 (53%) of the subjects in the Ca+D group were on HTN medication.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
11297596 | Pfeifer 2001 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
11297596 | Pfeifer 2001 | Demographics (e.g., age, gender, race, education)? | no
11297596 | Pfeifer 2001 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no
11297596 | Pfeifer 2001 | Medical conditions
11297596 | Pfeifer 2001 | Medication
11297596 | Pfeifer 2001 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
11297596 | Pfeifer 2001 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no
11297596 | Pfeifer 2001 | Other | | “Both tx groups were comparable concerning age, ht, wt, physical activity, concomitant diseases, and concomitant medication.”

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline SD * | Final ** | Final SD * | Net difference (CaD – Ca) | Net difference CI/SE/SD * | P between
11297596 | Pfeifer 2001 | SBP | mmHg | Ca + D | 8 wks | 73 | 144.1 | 20.4 | 131.0 | 16.9 | −7.4 | | 0.02
11297596 | Pfeifer 2001 | SBP | mmHg | Ca | 8 wks | 72 | 140.6 | 14.7 | 134.9 | 19.9
| | DBP | mmHg | Ca + D | 8 wks | 73 | 84.7 | 7.6 | 77.5 | 12.4 | −0.3 | | 0.10
| | DBP | mmHg | Ca | 8 wks | 72 | 82.6 | 6.4 | 75.7 | 12.5
| | 25(OH)D | nmol/L | Ca + D | 8 wks | 73 | 25.65 | 13.63 | 64.84 | 25.84 | | | <0.01
| | 25(OH)D | nmol/L | Ca | 8 wks | 72 | 24.63 | 12.14 | 44.36 | 27.38

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “− “ sign: e.g. +2.8 or −2.8

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
11297596 | Pfeifer 2001 | SBP | 60 (81%) of the subjects in the Ca+D group had a decrease in SBP > 5 mmHg compared to 35 (47%) in the Ca group (P = 0.04). 8 (11%) of the subjects in the Ca+D group had a increase in SBP > 5 mmHg compared to 29 (39%) in the Ca group (P = 0.05).
| | DBP | 58 (78%) of the subjects in the Ca+D group had a decrease in DBP > 5 mmHg compared to 36 (49%) in the Ca group (P = 0.1). 21 (28%) of the subjects in the Ca group had an increase in DBP > 5 mmHg compared to 10 (13%) in the Ca+D group (P = 0.02).

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
11297596 | Pfeifer 2001 | RCT parallel | nd | nd | NA | Y | nd | Y | Y | nd | Y | B
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | No data on randomization technique, allocation concealment, blinded outcome assessment, or assessment for confounding

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Pietinen 1999

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
10530608 | Pietinen 1999 | Cohort study Based on data collected during an RCT | Male smokers, 50–69 years of age at entry; recruited from the total male population of this age group in southwestern Finland; they had to smoke at least 5 cigarettes per day and to give written consent | History of cancer or other serious disease; use of vitamin E, vitamin A, or beta-carotene supplements in excess of predefined doses; and treatment with anticoagulant agents | nd | Alpha-Tocopherol, Beta-Carotene Cancer Prevention Study (ATBC Study) | US NCI | AT

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
10530608 | Pietinen 1999 | Cohort study Based on data collected during an RCT | Southwestern Finland | 27111 | 27111 | Median, cases: 60.1; non cases: 57.1 | nd | 100 | Finish | Median BMI (kg/m2), cases: 26.3 ; non cases: 26 | Physical activity (moderate), cases: 13.9; non cases: 25.8 Median daily alcohol intake (g), cases: 9.6; non cases: 11.2 | Median daily energy intake (kcal), cases: 2731; non cases: 2720 Median daily total protein intake(g), cases: 98; non cases: 100 Median daily total triglycerides intake (g), cases: 100; non cases: 101 Median daily saturated fatty acids intake (g), cases: 47.8; non cases: 50 Median daily monounsaturated fatty acids intake (g), cases: 35.2; non cases: 35 Median daily polyunsaturated fatty acids intake (g), cases: 10.2; non cases: 9.6 Median daily trans fatty acids intake (g), cases: 3; non cases: 2.9 Median daily dietary fiber intake (g), cases: 24.6; non cases: 24.2 Median daily calcium intake (mg), cases: 1286; non cases: 1338 Median daily vitamin D intake (mg), cases: 4.8; non cases: 4.8

UI | Author Year | Study Design* | Location (e.g., City and Country, latitude) | N enrolled*** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
10530608 | Pietinen 1999 | Cohort study Based on data collected during an RCT | Southwestern Finland | 27111 | 27111 | Median, cases: 60.1; non cases: 57.1 | nd | 100 | Finish | Median BMI (kg/m2), cases: 26.3 ; non cases: 26 | Physical activity (moderate), cases, %: 25.7 Median daily alcohol intake (g), cases: 9.6; non cases: 11.2 | Median daily milk products consumption (g), cases: 684; non cases: 735 Median daily whole grain products consumption (g), cases: 216; non cases: 212 Median daily vegetables consumption (g), cases: 103; non cases: 99 Median daily cruciferous vegetables consumption (g), cases: 16.1; non cases: 12.8 Median daily fruit consumption (g), cases: 111; non cases: 103 Median daily red meat consumption (g), cases: 125; non cases: 128

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
10530608 | Pietinen 1999 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | na | na | na | na | na
10530608 | Pietinen 1999 | Dietary calcium intake | FFQ | Food composition database at the National Public Health Institute, Finland; fatty acid content, fiber content of foods: analyses carried out at the Department of Food Chemistry, University of Helsinki | y Validation study of the dietary method carried out prior to the trial: correlation between the questionnaire-based, energy-adjusted intakes and those based on 24 days of food recording was 0.66 for calcium | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
10530608 | Pietinen 1999 | Secondary outcome | Colon cancer or rectal cancer | Inciden t cases of colon or rectal cancer (ICD-9) diagnosed between randomization and 30 April 1995, and identified through the Finnish Cancer Registry. All cases were reviewed centrally by two oncologists and a pathologist checked the original histological specimens.

UI | Author Year | Comments
10530608 | Pietinen 1999 | In cases of multiple colorectal cancers, the first one was chosen (n = 2), and when the tumors were diagnosed simultaneously, the most invasive one was chosen (n = 2). In one case with three simultaneous colorectal cancers, the data were combined, and the ICD-9 code not indicating a specific site within the colon was used. Average follow up: 8 years

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
10530608 | Pietinen 1999 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes (supplement group; calcium intake; energy adjustment)
10530608 | Pietinen 1999 | Demographics (e.g., age, gender, race, education)? | Yes [age (for 5-year categories); education]
10530608 | Pietinen 1999 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes [BMI (tertiles)]
10530608 | Pietinen 1999 | Medical conditions | No
10530608 | Pietinen 1999 | Medication | No
10530608 | Pietinen 1999 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | No
10530608 | Pietinen 1999 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes [smoking years (<35 vs. over); alcohol consumption (tertiles); occupational physical activity]
10530608 | Pietinen 1999 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

Adjusted for age (5-year categories) and supplement group

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non- cases/Total N ** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups *** | P for trend ****
10530608 | Pietinen 1999 | Colorectal cancer | 1 ^ st ^ quartile, total calcium intake, median (mg) | | 856 | 60 | nd | 96 | adjusted | RR | 1.0 | | | 0.04
| | | 2 ^ nd ^ quartile, total calcium intake, median (mg) | | 1241 | 41 | nd | 96 | adjusted | RR | 0.7 | 0.4–1.0 | nd | 0.04
| | | 3 ^ rd ^ quartile, total calcium intake, median (mg) | | 1484 | 45 | nd | 96 | adjusted | RR | 0.7 | 0.5–1.1 | nd
| | | 4 ^ th ^ quartile, total calcium intake, median (mg) | | 1789 | 39 | nd | 96 | adjusted | RR | 0.6 | 0.6–0.9 | nd

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

Adjusted for age (5-year categories), supplement group, smoking years, body mass index, alcohol, education, and physical activity at work, and calcium intake

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | No. of Non- cases/Total N** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups*** | P for trend****
10530608 | Pietinen 1999 | Colorectal cancer | 1 ^ st ^ quartile, total calcium intake, median (mg) | | 856 | 60 | nd | 96 | adjusted | RR | 1.0 | | | 0.04
| | | 2 ^ nd ^ quartile, total calcium intake, median (mg) | | 1241 | 41 | nd | 96 | adjusted | RR | 0.7 | 0.5–1.0 | nd | 0.04
| | | 3 ^ rd ^ quartile, total calcium intake, median (mg) | | 1484 | 45 | nd | 96 | adjusted | RR | 0.7 | 0.5–1.1 | nd | 0.04
| | | 4 ^ th ^ quartile, total calcium intake, median (mg) | | 1789 | 39 | nd | 96 | adjusted | RR | 0.6 | 0.6–0.9 | nd | 0.04

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
10530608 | Pietinen 1999 | The analyses were also redone excluding all cases from the first two years of follow-up, but this did not alter the results (data not shown). Type of analyses represents a cohort study and not an RCT

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
10530608 | Pietinen 1999 | a) Eligibility criteria clear? (y/n) | y | a) Exposure assessor blinded to outcome info? (y/n) | n | a) Method reported? (y/n) | y | a) One of the prespecified methods *** was used? (y/n) | na | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | a) Clear definition of outcome, including time of ascertainment? (y/n) | y | a) Prospective collection of data? (y/n) | y
10530608 | Pietinen 1999 | b) Sampling of population random or consecutive? (y/n) | n | b) Outcome assessor blinded to exposure measurement? (y/n) | n | b) Food composition database or suppl composition reported? (y/n) | y | Time from sample collection to sample analysis reported? (y/n) | na | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | b) Loss to follow-up <20%? (y/n) | y | b) Analysis was planned when cohort was formed? (y/n) | n
10530608 | Pietinen 1999 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | y | | | | | b) Justification of final adjusted model selection? (y/n) | y | c) Do the authors specify a primary outcome? (y/n) | y | c) Justification of sample size (includes sample size calculations)? (y/n) | n
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Assessor blinding not reported; power calculation not reported; post hoc analyses; number of non-cases per calcium quartile is not reported

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Platz 2000

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
11045788 | Platz 2000 | Case-cohort study | - Participants of NHS (i.e., female nurse, age 30–55 y) (n=121700); - Volunteer blood sample providers between 05/1989- 06/1991 (n=32826); - Undertook sigmoid- or colonoscopy between1989– 1996; - Free from cancer (except for nonmelanoma skin cancer); - Cases: newly diagnosed distal or rectal adenoma polyps confirmed by pathology reports (n=326); - Control: 1:1 matching controls by endoscopy during the same 2-year period, year of birth (age), indication(s) of endoscopy, time period of first and most recent endoscopy (n=326) | Cases:; - hyperplastic and other non-adenoma polyps; - adenoma polyps reported but not confirmed (7% or all reports) | 1976 | Nurses’ health study | NIH | JHL/TTe

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

Undetected proximal polyps can be either cases or controls

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
11045788 | Platz 2000 | Case- cohort study | US, various locations | 652 | 652 | 58.5±6.6 | nd | 0% | nd | BMI 25.0 kg/m2 Mean physical activity 15.4 METe- h/wk Mean solar exposure 352 langleys/d | Regular aspirin use: 26.1% Hormone replacement: 35.5% Prior negative endoscopy: 34.4% | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (e.g. blood sample or dietary assessment), number of subjects had outcome data ...etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
11045788 | Platz 2000 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | RIA | Intrapair coefficient of variation (CV) 1,25(OH)2D=9.9% 25(OH)D=7.5% | Nd ~6- ~11 y(earliest should be 1996 latest should be 2000) | Nd (but stratified analyses based on season of blood draw performed) | 1,25(OH) _ 2 _ D=31.9 pg/ml 25(OH)D=26.6 pg/ml Vit D=323 IU/d
11045788 | Platz 2000 | Dietary calcium intake | SFFQ | nd | nd | | | | | 984.5mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
11045788 | Platz 2000 | nd | (distal) colorectal polyps | Adenomatous polyps by review of histopathological reports.
11045788 | Platz 2000 | nd | (distal) colon polyps | Same as above
11045788 | Platz 2000 | nd | Rectal polyps | Same as above
11045788 | Platz 2000 | nd | “high-risk” (distal) colorectal polyps | Large (1 cm or larger), villous or tubulovillous adenoma
11045788 | Platz 2000 | nd | “low-risk” (distal) colorectal polyps | Small (<1 cm), tubular adenoma

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

Data on “low-risk” (distal) colorectal polyps were not extracted.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
11045788 | Platz 2000 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes: Intake of red meat and methionine, 1980 folic acid | Matching factors: endoscopy during the same 2-year period, year of birth, indication(s) for endoscopy, time period of first or most recent endoscopy excluding the one in the current time period, and date of blood draw Stratified analyses on: use of Vit D or Ca supplement, total intake of Vit D or Ca, daily solar UV irradiation, season of blood draw
11045788 | Platz 2000 | Demographics (e.g., age, gender, race, education)? | Yes–matched on age
11045788 | Platz 2000 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes - BMI
11045788 | Platz 2000 | Medical conditions | No
11045788 | Platz 2000 | Medication | Yes: Aspirin use, 1990 postmenopausal hormone use
11045788 | Platz 2000 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | Yes: physical activity
11045788 | Platz 2000 | Smoking and other life styles variables | Yes - smoking, alcohol consumption
11045788 | Platz 2000 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose ***** | Mean Ca level/dose | No. of Cases (Event) * | No. of Non- cases ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
11045788 | Platz 2000 | Distal colorectal adenoma | 1,25(OH)2D quartile 1 | 22.3 pg/ml | | 97 | 80 | Adjusted | OR | 1.00 (ref) | | | 0.4
| | | quartile 2 | 29.0 pg/ml | | 71 | 84 | | | 0.64 | 0.41–1.02
| | | quartile 3 | 33.9 pg/ml | | 84 | 80 | | | 0.80 | 0.50–1.30
| | | quartile 4 | 40.9 pg/ml | | 74 | 82 | | | 0.71 | 0.43–1.15
11045788 | Platz 2000 | Distal colorectal adenoma | 25(OH)D quartile 1 | 16.3 pg/ml | | 103 | 82 | Adjusted | OR | 1.00 (ref) | | | 1.0
| | | quartile 2 | 22.6 pg/ml | | 62 | 80 | | | 0.64 | 0.41–1.00
| | | quartile 3 | 28.3 pg/ml | | 61 | 82 | | | 0.58 | 0.36–0.95
| | | quartile 4 | 38.0 pg/ml | | 100 | 82 | | | 1.04 | 0.66–1.66
11045788 | Platz 2000 | Rectal adenoma | 1,25(OH)2D quartile 1 | 22.3 pg/ml | | 16 | 17 | Adjusted | OR | 1.00 (ref) | | | 0.9
| | | quartile 2 | 29.0 pg/ml | | 18 | 14 | | | 1.35 | 0.41–4.43
| | | quartile 3 | 33.9 pg/ml | | 13 | 16 | | | 0.58 | 0.16–2.09
| | | quartile 4 | 40.9 pg/ml | | 18 | 18 | | | 1.06 | 0.30–3.73
11045788 | Platz 2000 | Rectal adenoma | 25(OH)D quartile 1 | 16.3 pg/ml | | 24 | 18 | Adjusted | OR | 1.00 (ref) | | | 0.9
| | | quartile 2 | 22.6 pg/ml | | 7 | 16 | | | 0.38 | 0.12–0.19
| | | quartile 3 | 28.3 pg/ml | | 10 | 13 | | | 0.34 | 0.08–1.42
| | | quartile 4 | 38.0 pg/ml | | 24 | 18 | | | 1.59 | 0.50–5.03
11045788 | Platz 2000 | Distal colon adenoma | 1,25(OH)2D quartile 1 | 22.3 pg/ml | | 81 | 63 | Adjusted | OR | 1.00 (ref) | | | 0.2
| | | quartile 2 | 29.0 pg/ml | | 53 | 70 | | | 0.51 | 0.30–0.86
| | | quartile 3 | 33.9 pg/ml | | 71 | 64 | | | 0.78 | 0.45–1.34
| | | quartile 4 | 40.9 pg/ml | | 56 | 64 | | | 0.60 | 0.34–1.04
11045788 | Platz 2000 | Distal colon adenoma | 25(OH)D quartile 1 | 16.3 pg/ml | | 79 | 64 | Adjusted | OR | 1.00 (ref) | | | 1.0
| | | quartile 2 | 22.6 pg/ml | | 55 | 64 | | | 0.71 | 0.43–1.18
| | | quartile 3 | 28.3 pg/ml | | 51 | 69 | | | 0.60 | 0.35–1.02
| | | quartile 4 | 38.0 pg/ml | | 76 | 64 | | | 1.02 | 0.60–1.73
11045788 | Platz 2000 | Distal colorectal adenoma | 25(OH)D | nd | | nd | nd | Adjusted (after 2 years from blood draw only) | OR | 1.00 (ref) | nd | | Nd “comparable to main analysis”
| | | | | | | | | | 0.73 | nd
| | | | | | | | | | 0.85 | nd
| | | | | | | | | | 0.96 | nd
11045788 | Platz 2000 | Distal colorectal adenoma | 1,25(OH)D quartile 1 | nd | | nd | nd | Adjusted (season of blood draw taken into account) | OR | 1.00 (ref) | nd | | Nd “comparable to main analysis”
| | | quartile 2 | | | | | | | 0.64 | nd
| | | quartile 3 | | | | | | | 0.75 | nd
| | | quartile 4 | | | | | | | 0.68 | nd
11045788 | Platz 2000 | “high-risk” distal colon cancer | 25(OH)D quartile 1 | 16.3 | | 45 | 36 | Adjusted | OR | 1.00 (ref) | | | 0.9
| | | quartile 2 | 22.6 | | 24 | 37 | | | 0.54 | 0.25–1.16
| | | quartile 3 | 28.3 | | 26 | 35 | | | 0.67 | 0.31–1.44
| | | quartile 4 | 38.0 | | 47 | 34 | | | 1.30 | 0.59–2.86

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

***** median

MEAN DATA

THIS SHOULD ONLY APPLY TO CASE-COHORT STUDIES THAT COMPARE BASELINE VIT D/CA LEVELS BETWEEN CASES (WITH DISEASE) AND CONTROLS (WITHOUT DISEASE)

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Mean 25(OH)D Level | Vit D level SD* | Mean Ca intake or Ca balance | Ca SD* | P between groups
11045788 | Platz 2000 | Cases: | −7y | Adjusted | 326 | 31.6 pg/ml | 8.4 | | | 0.3
| | Control: | −7y | (matching) | 326 | 32.2 pg/ml | 8.6
11045788 | Platz 2000 | Cases: | | Adjusted | 326 | | | 977 mg/d | 334 | 0.6
| | Control: | | (matching) | 326 | | | 992 mg/d | 332

Duplicate one table per outcome

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
11045788 | Platz 2000 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | nd | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | Y | a) Level of the exposure in comparative categories (e.g. quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
11045788 | Platz 2000 | b) Sampling of population random or consecutive? (y/n) | nd | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | N | a) Level of the exposure in comparative categories (e.g. quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | nd | b) Analysis was planned when cohort was formed? (y/n) | N
11045788 | Platz 2000 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | N | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Some unclear reporting (inclusion and blinding) and retrospective analyses of an existing cohort, no internal calibration of SFFQ

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Platz 2004 and Mikhak 2007

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
15090720 and 17440943 | Platz 2004 and Mikhak 2007 | Case- cohort study | available blood specimen, white male (Mikhak) | cancer prior to blood drawn (except for nonmelanoma skin cancer); T1a prostate cancer | 1993–95 | Health Professionals Follow-up Study | government | SI, KP (for Mikhak study)

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
15090720 | Platz 2004 | Case- cohort study | NE, S, W, Midwest US | 920 (460 cases and 460 controls) | 920 | 66.5 (7.4) | nd | 100 | 6% non- white | BMI 22.8 | 18% smoker; DM 3.6% | 448 IU/d of vit D; 962 mg/d of calcium
17440943 | Mikhak 2007 | Case- cohort study | NE, S, W, Midwest US | 51,529 in original cohort, 1408 in case-control (704 each for cases and controls) | 1366 | 66 (7) | nd | 100 | 100% white | nd | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
15090720 | Platz 2004 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | RIA | y; 2 separate analytical runs; intrapair CV 5.4%, 5.6% for 25OH-D; 5.3%, 7.3% for 1,25 OH-D | nd | nd; but cases matched to controls for season of blood drawn | Vit D (IU/day): cases = 459(268) ;controls = 436(271)
17440943 | Mikhak 2007 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | RIA for 25(OH)D, radioceptor assay with calf thymus receptors for 1,25(OH)D | nd | nd | nd | nd
15090720 | Platz 2004 | Dietary calcium intake | nd | nd | nd | | | | | Calcium (mg/day): cases= 975(474); controls = 950(455)
17440943 | Mikhak 2007 | Dietary calcium intake | Nd | Nd | Nd | | | | | Nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
15090720 | Platz 2004 | primary | prostate cancer | deaths, diagnosis or self-reported
17440943 | Mikhak 2007 | Nd | Prostate cancer | Deaths, diagnosis, or self-reported

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
15090720 | Platz 2004 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | yes; intake of energy, red meat, fish, lycopene, fructose and α-linolenic acid, vit E, Se, Ca and vit D
15090720 | Platz 2004 | Demographics (e.g., age, gender, race, education)? | Yes
15090720 | Platz 2004 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes
15090720 | Platz 2004 | Medical conditions | DM; vasectomy
15090720 | Platz 2004 | Medication
15090720 | Platz 2004 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | yes; season, location
15090720 | Platz 2004 | Smoking and other life styles variables | Yes; smoking
15090720 | Platz 2004 | Other
17440943 | Mikhak 2007 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes | Total intake of tomato sauce, alcohol, energy, fish, calcium, retinol, alpha linolenic acid, vitamin E supplement use, selenium supplement use
| | Demographics (e.g., age, gender, race, education)? | Yes | Age (match), race
| | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI
| | Medical conditions | Family history of prostate cancer
| | Medication
| | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | Yes | Region of residence
| | Smoking and other life styles variables | Yes | Smoking status
| | Other | History of PSA test before blood draw (match), quadrant of day of blood draw (match), year of blood draw (match)

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | Result | 95% CI | P btw
17440943 | Mikhak 2007 | Total prostate cancer | 25(OH)D <= 15 ng/ml | Nd | 627 | 1231 | OR: 25(OH)D deficient/non- deficient | 0.63 | 0.44–0.90 | nd | 0.62 | 0.43–0.91 | 0.01
17440943 | Mikhak 2007 | Total prostate cancer | 25(OH)D > 15 ng/ml | Nd | 57 | 145 | OR: 25(OH)D deficient/non- deficient | 0.63 | 0.44–0.90 | nd | 0.62 | 0.43–0.91 | 0.01
| | Total prostate cancer | 1,25(OH)D <= 26 pg/ml | Nd | 565 | 1151 | OR: 1,25(OH)D deficient/non-deficient | 1.22 | 0.89–1.65 | nd | 1.25 | 0.91–1.73 | nd
| | Total prostate cancer | 1,25(OH)D > 26 pg/ml | Nd | 119 | 225 | OR: 1,25(OH)D deficient/non-deficient | 1.22 | 0.89–1.65 | nd | 1.25 | 0.91–1.73 | nd

* Example: OR Ca/placebo

Note: unadjusted model still matched for matching factors as listed in confounder table

≥ 2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non- cases/Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
15090720 | Platz 2004 | Prostate cancer | 25 OH-D; Quartile * (separate cut points by analytical run (there were 2); season of the year and distributions among control, see Table 3 in paper) | Quartile 1 | | 109 | 114 | mutually adjusted for 1,25 and 25-OH-D using conditional logistic regression | OR | 1.00 (Ref) | | | 0.41
| | | | Quartile 2 | | 115 | 113 | | | 1.05 | 0.71–1.54
| | | | Quartile 3 | | 94 | 120 | | | 0.82 | 0.56–1.20
| | | | Quartile 4 | | 142 | 113 | | | 1.27 | 0.86–1.86
| | | | Quartile 1 | | 109 | 114 | mutually adjusted for 1,25 and 25-OH-D; FH; ht; physical activity; DM; vasectomy; smoking, diet; vit E, Se supplements using conditional logistic regression | OR | 1.00 (Ref) | | | 0.59
| | | | Quartile 2 | | 115 | 113 | | | 1.00 | 0.67–1.49
| | | | Quartile 3 | | 94 | 120 | | | 0.77 | 0.51–1.15
| | | | Quartile 4 | | 142 | 113 | | | 1.19 | 0.79–1.79
| | | 1,25 OH-D | Quartile 1 | | 102 | 110 | mutually adjusted for 1,25 and 25-OH-D using conditional logistic regression | | 1.00 (Ref) | | | 0.16
| | | | Quartile 2 | | 103 | 115 | | | 0.99 | 0.67–1.45
| | | | Quartile 3 | | 120 | 122 | | | 1.08 | 0.73–1.61
| | | | Quartile 4 | | 135 | 113 | | | 1.25 | 0.83–1.88
| | | | Quartile 1 | | 102 | 110 | mutually adjusted for 1,25 and 25-OH-D; FH; ht; physical activity; DM; vasectomy; smoking, diet; vit E, Se supplements using conditional logistic regression | | 1.00 (Ref) | | | 0.16
| | | | Quartile 2 | | 103 | 115 | | | 0.93 | 0.62– 1.39
| | | | Quartile 3 | | 120 | 122 | | | 1.04 | 0.69–1.56
| | | | Quartile 4 | | 135 | 113 | | | 1.25 | 0.82–1.90

* From Platz 2004, table 3 footnotes:

Medians for each quartile: Among controls matched to cases diagnosed between date of blood draw and 1/1996: 25(OH)D - summer: 20.1, 24.1,27.6,32.9; fall: 14.9,22.4,25.4,31.1; spring: 12.0, 16.6,20.9,24.5; winter: 9.3, 15.8, 19.9,24.6. I,25(OH)D - summer: 27.0, 31.0, 35.7, 42.6; fall: 26.8, 30.1, 34.4, 39.9; spring: 25.6, 28.9, 33.7, 37.1; winter: 19.1 27.1,33.5,39.2. Ratio (xIO-3) - summer: 0.89,1.25,1.38,1.90; fall: 0.99,1.20, 1.54,2.11; spring: 1.00, 1.54, 1.88,2.78; winter: 1.06, 1.42, 1.81,2.84. Among controls matched to cases diagnosed 2/1996 - 1/1998: 25(OH)D in ng/ml- summer: 17.4,23.8,28.4,36.5; fall: 16.8,22.0,27.7,38.2; spring: 13.9, 19.7,24.0,29.9; winter: 13.8, 19.4,21.8,26.9. 1,25(OH)D in pg/ml - summer: 25.5, 30.6, 37.3, 45.2; fall: 27.5, 31.9, 36.7,44.0; spring: 25.0, 30.0, 34.3, 38.8; winter: 27.6, 31.7, 36.8, 39.9. Ratio (xI0-3) - summer: 0.88; 1.11, 1.47, 1.96; fall: 0.95, 1.14, 1.54,2.10; spring: 0.91, 1.33, 1.56,2.19; winter: 1.14, 1.50, 1.84,2.70.

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

MEAN DATA

THIS SHOULD ONLY APPLY TO CASE-COHORT STUDIES THAT COMPARE BASELINE VIT D/CA LEVELS BETWEEN CASES (WITH DISEASE) AND CONTROLS (WITHOUT DISEASE)

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Mean 25(OH)D Level | Vit D level SD* | Mean Ca intake or Ca balance | Ca CI/SE/SD* | P between groups
15090720 | Platz 2004 | Cases: | 2.2 ± 1.2 y | crude | 460 | 24.6 ng/mL | 7.7 | | | 0.20
| | Control: | | | 460 | 23.9 ng/mL | 8.2

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Mean 1,25(OH)D Level | Vit D level SD* | Mean Ca intake or Ca balance | Ca CI/SE/SD* | P between groups
15090720 | Platz 2004 | Cases: | 2.2 ± 1.2 y | crude | 460 | 34.3 pg/mL | 7.1 | | | 0.06
| | Control: | | | 460 | 33.5 pg/mL | 7.1

Duplicate one table per outcome

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
17440943 | Mikhak 2007 | Prostate cancer | No significant differences in 25(OH)D or 1,25(OH)D between cases and matched controls, as well as no differences in quintile trend.

UI | Author Year | Comments for Results
15090720 | Platz 2004 | mean time between blood drawn and diagnosis was 2.2 ± 1.2 y

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
15090720 and 17440943 | Platz 2004 and Mikhak 2007 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | N | a) Method reported? (y/n) | N | a) One of the prespecified methods *** was used? (y/n) | Y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
15090720 and 17440943 | Platz 2004 and Mikhak 2007 | b) Sampling of population random or consecutive? (y/n) | N | b) Outcome assessor blinded to exposure measurement? (y/n) | Y | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | N | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
15090720 and 17440943 | Platz 2004 and Mikhak 2007 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Platz did not adjust for calcium intake (Mikhak did), Mikhak does not describe how cancer cases and staging were ascertained, nor do the total cases match up from text to result table (Table 3).

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence