# Evidence Tables: F-K

## Feliciano 1994

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
8078115 | Feliciano 1994 | RCT | ≥37 wk gestation | gastrointestinal disease; congenital anomalies | Fall 1986; Spring 1987 | - | non-profit | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location(e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake…etc.)
8078115 | Feliciano 1994 | RCT | Beijing (40 ºN); Jiamusi (47 ºN); Nanin (22ºN); Wuhan (30ºN) China | 255 | 255 | newborn | | nd | Asians | 6 mo weight: 7.8 Kg; length; 67 cm

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
8078115 | Feliciano 1994 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | nd | | | 86% infant breastfed until 5–6 mo; other foods: powdered cow milk; rice porridge
| | Dietary calcium intake

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
8078115 | Feliciano 1994 | | Kremers-Urban Co., Milwaukee, WI | 100 IU | 6 mo | nd
| | | | 200 IU
| | | | 400 IU
Co-intervention(s) * :
Compliance/Adherence:

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
8078115 | Feliciano 1994 | primary | weight
| | primary | length

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
8078115 | Feliciano 1994 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
8078115 | Feliciano 1994 | Demographics (e.g., age, gender, race, education)? | no *
8078115 | Feliciano 1994 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no *
8078115 | Feliciano 1994 | Medical conditions
8078115 | Feliciano 1994 | Medication
8078115 | Feliciano 1994 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
8078115 | Feliciano 1994 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no *
8078115 | Feliciano 1994 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure Category/Intervention Group | Crude or Adjusted analysis? | Mean Follow-up (months) | No. Analyzed | Baseline | Baseline CI/SE/SD * | Delta ** | Final or Delta CI/SE/SD * | Net difference *** | Net difference CI/SE/SD * | P between groups ***
8078115 | Feliciano 1994 | weight gain in North, born in spring | g | 100 IU | | 6 mo | 17 | | | 4208 | 1695 | | | NS
| | weight gain in North, born in spring | | 200 IU | | | 13 | | | 5296 | 1064
| | weight gain in North, born in spring | | 400 IU | | | 12 | | | 3745 | 2000
| | weight gain in North, born in fall | g | 100 IU | | 6 mo | 15 | | | 5190 | 927 | | | NS
| | weight gain in North, born in fall | | 200 IU | | | 13 | | | 5046 | 862
| | weight gain in North, born in fall | | 400 IU | | | 13 | | | 4846 | 763
| | weight gain in South, born in spring | g | 100 IU | | 6 mo | 15 | | | 4810 | 873 | | | NS
| | weight gain in south, born in spring | | 200 IU | | | 20 | | | 4536 | 706
| | weight gain in south, born in spring | | 400 IU | | | 20 | | | 4609 | 1005
| | weight gain in South, born in fall | g | 100 IU | | | 21 | | | 4563 | 958 | | | NS
| | weight gain in south, born in fall | | 200 IU | | | 19 | | | 4342 | 585
| | weight gain in south, born in fall | | 400 IU | | | 23 | | | 4572 | 671
| | Length gain in North, born in spring | cm | 100 IU | | | 15 | | | 19.3 | 3.6 | | | NS
| | Length gain in North, born in spring | | 200 IU | | | 13 | | | 19 | 1.7
| | Length gain in North, born in spring | | 400 IU | | | 12 | | | 18.8 | 2.4
| | Length gain in North, born in fall | cm | 100 IU | | | 18 | | | 17.9 | 3.0 | | | NS
| | Length gain in North, born in fall | | 200 IU | | | 15 | | | 17.5 | 1.9
| | Length gain in North, born in fall | | 400 IU | | | 16 | | | 18.7 | 3.5
| | Length gain in South, born in spring | cm | 100 IU | | | 15 | | | 16.6 | 1.7 | | | NS
| | Length gain in South, born in spring | | 200 IU | | | 20 | | | 16.6 | 2.1
| | Length gain in South, born in spring | | 400 IU | | | 20 | | | 16.7 | 1.8
| | Length gain in South, born in fall | cm | 100 IU | | | 22 | | | 15.6 | 1.8 | | | NS
| | Length gain in South, born in fall | | 200 IU | | | 10 | | | 16.5 | 3.4
| | Length gain in South, born in fall | | 400 IU | | | 23 | | | 17.1 | 3.7

Duplicate one row per exposure category or intervention group. Please write “nd” if there was no data reported. DO NOT LEAVE BLANK.

* Please choose one and delete the others

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
8078115 | Feliciano 1994 | unclear if it is randomized within each city or randomized in the overall study

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
8078115 | Feliciano 1994 | RCT | nd | n | NA | y | n | n | y | n | n | C
Adverse Event(s): **
Explanation for Overall Quality Grade (if not Grade A): | | | | | | incomplete reporting of study methodology; small number of subjects in each group

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Feskanich 2004

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
15342452 | Feskanich 2004 | Case-cohort study | - Ongoing cohort study with participants who were ages 30–55y at study initiation (N=121,700); - Subjects provided blood samples aged 43–70 y between 06/89-(12/)90 (N=32,826); - Cases: confirmed invasive adenocarcinoma (inferred) diagnosed between 1989-06/2000; - Controls: 1:2 matching cases (year of birth [=age], month of blood draw) | - Previous non-cutaneous cancer (in cases and controls); - Non-adenocarcinoma (SCC, CIS, metastatic) (in cases) (n=32); - Non-confirmed cases (in cases) (n=26) | 1976 | Nurses’ Health Study | nd | JHL/TTe

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
15342452 | Feskanich 2004 | Case-cohort study | US (various latitudes) | Original cohort (N=121,700), Subjects provided blood samples (N=32,826), cases (N=193) and controls (N=383) | 576 | 60 (no SD) | 43–70 (inclusion) | 0% | nd | BMI 25.1 | Aspirin user (>10y): 10% HRT user: 34% | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
15342452 | Feskanich 2004 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | RIA | Intraset coefficient of variation (CV) based on 21 masked samples from cases and controls: 25(OH)D=11.8% 1,25(OH)2D=10.1% | ~10 y or 13 y | nd | Total Vit D intake: 9.3 g/d, 25(OH)D 24.1ng/mL
15342452 | Feskanich 2004 | Dietary calcium intake | FFQ | nd | nd | nd | nd | | | Total Ca intake: 1049.2 mg/day

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
15342452 | Feskanich 2004 | nd | Colorectal cancer | - Reported by a participant on a NHS questionnaire; - Invasive adenocarcinoma (inferred) confirmed by medical records (96%) or by the participants by letter or telephone incase medical records were unavailable; - Identified cases from death record information
15342452 | Feskanich 2004 | nd | Colon cancer | nd
15342452 | Feskanich 2004 | nd | Rectal cancer | nd
15342452 | Feskanich 2004 | nd | Proximal and distalcolon cancer | nd

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
15342452 | Feskanich 2004 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Intakes of calcium, folate, methionine, retinol, red meat | Matching factors: year of birth, month of blood draw # sensitivity analysis: cases diagnosed within the first year after blood draw excluded and average UV light at zip code of residence added to the full model (results not materially changed [data not shown]).
15342452 | Feskanich 2004 | Demographics (e.g., age, gender, race, education)? | Yes – matched on age
15342452 | Feskanich 2004 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes - BMI
15342452 | Feskanich 2004 | Medical conditions
15342452 | Feskanich 2004 | Medication | Use of HRT, duration of aspirin use
15342452 | Feskanich 2004 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | Physical activity
15342452 | Feskanich 2004 | Smoking and other life styles variables | Yes - pack years of smoking, alcohol
15342452 | Feskanich 2004 | Other | Family history of colorectal cancer, menopausal status

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose ***** (ng/mL) | | Mean Ca level/dose | No. of Cases (Event) * | No. of Non- cases ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
15342452 | Feskanich 2004 | Colorectal cancer | 25(OH)D – quintile 1 | Lab1 14.9 | Lab2 17.4 | | 53 | 77 | Adjusted | OR | 1.0 (ref) | | | 0.02
| | | 25(OH)D – quintile 2 | 19.6 | 24.8 | | 47 | 79 | Adjusted | | 0.93 | 0.53– 1.63
| | | 25(OH)D – quintile 3 | 24.1 | 29.6 | | 35 | 75 | Adjusted | | 0.79 | 0.44–1.40
| | | 25(OH)D – quintile 4 | 27.9 | 34.5 | | 29 | 77 | Adjusted | | 0.58 | 0.31–1.07
| | | 25(OH)D – quintile 5 | 35.3 | 44.5 | | 29 | 75 | Adjusted | | 0.53 | 0.27–1.04
15342452 | Feskanich 2004 | Colorectal cancer | 1,25(OH)2D – quintile 1 | 24.6 | 18.7 | | 34 | 77 | Adjusted | OR | 1.0 (ref) | | | 0.51
| | | 1,25(OH)2D – quintile 2 | 29.4 | 24.2 | | 42 | 78 | Adjusted | | 1.45 | 0.78–2.69
| | | 1,25(OH)2D – quintile 3 | 33.2 | 29.8 | | 33 | 76 | Adjusted | | 0.93 | 0.48–1.78
| | | 1,25(OH)2D – quintile 4 | 36.8 | 33.8 | | 38 | 76 | Adjusted | | 1.21 | 0.64–2.26
| | | 1,25(OH)2D – quintile 5 | 43.7 | 42.3 | | 46 | 75 | Adjusted | | 1.77 | 0.93–3.36

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

***** median from lab 1 and lab 2, lab 1 values are from blood samples assayed in 2000. lab2 values are from blood samples assayed 2003.

MEAN DATA

THIS SHOULD ONLY APPLY TO CASE-COHORT STUDIES THAT COMPARE BASELINE VIT D/CA LEVELS BETWEEN CASES (WITH DISEASE) AND CONTROLS (WITHOUT DISEASE)

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Mean 25(OH)D Level | Vit D level CI/SE/SD* | Mean Ca intake or Ca balance | Ca CI/SE/SD* | P between groups
15342452 | Feskanich 2004 | Cases: | 11y | Adjusted ** | 193 | | | 1004 mg
| | Control: | 11y | Adjusted ** | 383 | | | 1072 mg

Duplicate one table per outcome

** Adjusted by age

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
15342452 | Feskanich 2004 | Colon cancer | 25(OH)D (values for each quartile not provided) exhibited an inverse linear association, but was not significant (p=0.17).
15342452 | Feskanich 2004 | Rectal cancer | 25(OH)D (values for each tertile not provided) exhibited a strong inverse linear association (p=0.03).
15342452 | Feskanich 2004 | Cancer at the distal colon and rectum | A significant inverse dose-response association with 25(OH)D (p=0.02).
15342452 | Feskanich 2004 | Colorectal cancer | Sensitivity analysis: cases diagnosed within the first year after blood draw excluded and average UV light at zip code of residence added to the full model (results not materially changed [data not shown]).
15342452 | Feskanich 2004 | Colorectal cancer | Some post-hoc subgroup analyses:; - Vit D intake high (≥7.5 μg/d) and low (<7.5 μg/d) “association remained inverse”; - UV light high lesion → OR between Q1 & Q5: 0.25 [0.10–0.69] vs. low lesion→ OR: 1.24 [0.42–3.64] (Interaction between group P=0.16); - Ca intake high (≥ 900 mg/d) [Trend P=0.08] vs. low (<900 mg/d) [Trend P=0.14] “no evidence of attribution”
15342452 | Feskanich 2004 | Colorectal cancer | Subgroup Women Age ≥ 60: OR between Q1 & Q5 = 0.35 (0.14–0.87); Trend P=0.006
15342452 | Feskanich 2004 | Colorectal cancer | Subgroup Women Age < 60: OR between Q1 & Q5 = 1.36 (0.48–3.92); Trend P=0.70
15342452 | Feskanich 2004 | Colorectal cancer | Postmenoposal HRT user: OR between Q1 & Q5 = 0.61 (0.16–2.41); Trend P not reported
15342452 | Feskanich 2004 | Colorectal cancer | Postmenoposal non HRT user: OR between Q1 & Q5 = 0.41 (0.15–1.12); Trend P not reported

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
15342452 | Feskanich 2004 | a)Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | Y | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | Y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
15342452 | Feskanich 2004 | b) Sampling of population random or consecutive? (y/n) | nd | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | N | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | NA | b) Analysis was planned when cohort was formed? (y/n) | nd
15342452 | Feskanich 2004 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | | c) Do the authors specify a primary outcome? (y/n) | | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B ****
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Some unclear/no reporting, no internal calibration of FFQ

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

**** C (Grade for subgroup analysis - No information on range of plasma 25(OH)D for quartiles or tertiles)

## Flood 2005

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
15668485 | Flood 2005 | Cohort study | - Women found to or not to have breast disease participated in the BCDDP from 1973–1980(n=64182); - Completed baseline questionnaire from 1979–1981(n=61431) | - Failed to complete dietary assessment questionnaire from 1987–1989 (n=9738); - Already with colorectal cancer at the dietary assessment or earlier (n=479); - Reported an incorrect order of entry date and exit date (n=6); - Skipped >30 items of the dietary assessment or reported>3800 or <400 kcal/d total energy intake (n=5647); - Reported implausibly high Ca intake >3000 mg/d (n=207) # | 1973–1980 | The Breast Cancer Detection Demonstration Project (BCDDP) | NCI and American Cancer Society | TTE

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

# Although not provided, this exclusion seems to have been used in sensitivity analysis, which did not materially alter the results.

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
15668485 | Flood 2005 | Cohort | 27 cities across the US (25° 46′–54° 40′) | 61431 | 45354 (details on the reasons for exclusions spelled out above) | 61.9 (nd) | nd | 0% | nd | BMI=24.7 kg/m2 Ht=64.0 (inches) | Some with previous breast cancer (details not reported) | Total energy intake ~1273 kcal/d

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
15668485 | Flood 2005 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | nd | nd | nd | Nd
15668485 | Flood 2005 | Dietary calcium intake | 62-item National Cancer Institute/Block FFQ | USDA | Y (cited two original Block papers and a NCI paper) | nd | nd | | nd | Nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
15668485 | Flood 2005 | Nd | Colorectal cancer | Self reports, statewide cancer registry, national death index. Only self reports were validated by obtaining the pathology reports (94% confirmed). Cases without the pathology confirm were excluded in sensitivity analysis, which did not materially alter the results. Non-confirmed cases by the pathology reports not appearing in the registry were considered non-cases
| | nd | Colon cancer vs. rectal cancer | Same as above
| | | Proximal vs. distal colon cancer | Same as above (not data extracted)

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
15668485 | Flood 2005 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | folate, vitamin D, fiber, meat, fat, fruits, vegetables, grains, energy
15668485 | Flood 2005 | Demographics (e.g., age, gender, race, education)? | Age, education (through high school/more than high school)
15668485 | Flood 2005 | Anthropometrics (e.g., BMI, body weight, % body fat)? | body mass index (kg/m2), height
15668485 | Flood 2005 | Medical conditions | history of menopausal or hormone replacement therapy (yes/no)
15668485 | Flood 2005 | Medication | Non-steroidal anti-inflammatory (NSAID) drug use (yes/no)
15668485 | Flood 2005 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | No
15668485 | Flood 2005 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | smoking (ever/never), alcohol, weekday physical activity index expressed in units of Metabolic Equivalent Time
15668485 | Flood 2005 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

1. After performing all of these tests, none of the factors listed above generated any material changes in either the dietary calcium model, the total calcium model, or the supplemental calcium model (data not shown), and the authors did not include them in any of the final calcium models.

2. Adjusting for reported colorectal cancer -screening or restricting the cohort to only those subject s who had no prior history of breast disease result ed in no qualitative differences in risk estimates

3. Simultaneous inclusion of all these potential confounders in the proportional hazards regression models also did not produce any material changes in the results from those obtained in the age- and energy-adjusted models.

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level | Mean Ca level/dose | No. of Cases (Event) * | Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups *** | P for trend ****
15668485 | Flood 2005 | Colorectal cancer (Total calcium [mg]) | Q1 | 17 | <472 | 102 | nd | Age and energy only | RR (HR) | 1.00 | Ref | Nd | 0.02
| | | Q2 | 17 | 472–635 | 110 | nd | Age and energy only | RR (HR) | 1.03 | 0.79–1.35 | Nd
| | | Q3 | 17 | 636–844 | 86 | nd | Age and energy only | RR (HR) | 0.80 | 0.60–1.06 | Nd
| | | Q4 | 17 | 845–1270 | 106 | nd | Age and energy only | RR (HR) | 0.96 | 0.73–1.26 | Nd
| | | Q5 | 17 | >1270 | 80 | nd | Age and energy only | RR (HR) | 0.74 | 0.55–0.99 | Nd
15668485 | Flood 2005 | Rectal cancer(Total calcium [mg]) | Q1 | 17 | <472 | nd | nd | Age and energy only | RR (HR) | 1.00 | Ref | Nd | 0.30
| | | Q2 | 17 | 472–635 | nd | nd | Age and energy only | RR (HR) | 1.19 | 0.57–2.48 | Nd
| | | Q3 | 17 | 636–844 | nd | nd | Age and energy only | RR (HR) | 1.10 | 0.52–2.32 | Nd
| | | Q4 | 17 | 845–1270 | nd | nd | Age and energy only | RR (HR) | 1.23 | 0.60–2.53 | Nd
| | | Q5 | 17 | >1270 | nd | nd | Age and energy only | RR (HR) | 0.93 | 0.43–2.01 | Nd
15668485 | Flood 2005 | Colon cancer (Total calcium [mg]) | Q1 | 17 | <472 | nd | nd | Age and energy only | RR (HR) | 0.68 | 0.42–1.08 | Nd | 0.10
| | | Q2 | 17 | 472–635 | nd | nd | Age and energy only | RR (HR) | 0.83 | 0.53–1.29 | Nd
| | | Q3 | 17 | 636–844 | nd | nd | Age and energy only | RR (HR) | 0.54 | 0.33–0.90 | Nd
| | | Q4 | 17 | 845–1270 | nd | nd | Age and energy only | RR (HR) | 0.89 | 0.57–1.38 | Nd
| | | Q5 | 17 | >1270 | nd | nd | Age and energy only | RR (HR) | 1.0 | Ref | Nd
15668485 | Flood 2005 | Proximal colon cancer (Total calcium [mg]) | Q1 | 17 | <472 | nd | nd | Age and energy only | RR (HR) | 0.71 | 0.40–1.26 | Nd | 0.24
| | | Q2 | 17 | 472–635 | nd | nd | Age and energy only | RR (HR) | 0.71 | 0.40–1.26 | Nd
| | | Q3 | 17 | 636–844 | nd | nd | Age and energy only | RR (HR) | 0.86 | 0.49–1.49 | Nd
| | | Q4 | 17 | 845–1270 | nd | nd | Age and energy only | RR (HR) | 0.76 | 0.43–1.34 | Nd
| | | Q5 | 17 | >1270 | nd | nd | Age and energy only | RR (HR) | 1.0 | Ref | Nd
15668485 | Flood 2005 | Distal colon cancer (Total calcium [mg]) | Q1 | 17 | <472 | nd | nd | Age and energy only | RR (HR) | 1.00 | Ref | Nd | 0.26
| | | Q2 | 17 | 472–635 | nd | nd | Age and energy only | RR (HR) | 0.84 | 0.59–1.18 | Nd
| | | Q3 | 17 | 636–844 | nd | nd | Age and energy only | RR (HR) | 0.66 | 0.46–0.96 | Nd
| | | Q4 | 17 | 845–1270 | nd | nd | Age and energy only | RR (HR) | 0.78 | 0.55–1.11 | Nd
| | | Q5 | 17 | >1270 | nd | nd | Age and energy only | RR (HR) | 0.69 | 0.48–0.99 | Nd

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
15668485 | Flood 2005 | Some data on Vit D reported< br > Correlation between dietary Ca and supplemental Ca was low (r=0.01) Correlation between dietary Ca and dietary Vit D was high (r=0.87) Correlation between dietary Ca and total Vit D was low (r=0.33) Correlation between supplemental Ca and total Vit D was low (r=0.10) Explanation of the use of only age and energy adjusted model< br > Simultaneous inclusion of all the potential confounders in the proportional hazards regression models did not produce any material changes in the results from those obtained in the age- and energy-adjusted models.

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
19001601 | Flood 2008 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | Nd | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y but not used eventually | a) Clear definition of outcome, including time of ascertainment? (y/n) | y | a) Prospective collection of data? (y/n) | Y
19001601 | Flood 2008 | b) Sampling of population random or consecutive? (y/n) | Y “all” | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y but not used eventually | b) Loss to follow-up <20%? (y/n) | Y (90.3%) | b) Analysis was planned when cohort was formed? (y/n) | N
19001601 | Flood 2008 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | y | | | | | b) Justification of final adjusted model selection? (y/n) | Y “not materially altered” | c) Do the authors specify a primary outcome? (y/n) | n | c) ustification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C) | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Post-hoc analysis of an already available database. Otherwise, the reporting is good except for the blinding of the assessors of exposure and outcomes; not all cases confirmed by histology; participants per calcium quintile not reported; power calculation not reported

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Ford 1991

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
1937662 | Ford 1991 | Cohort study | 25–74 yo Traced between 1982–84 Detailed exam/interview Serum Ca available | HTN at baseline | 1971–75 | NHANES I | nd | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
1937662 | Ford 1991 | Cohort study | US, various | 6913 | 5411 | nd | 25–44: ~59% 45–64: ~28%≥65: ~13% | 35% | White: 88% Black: 12% | “Normal”: BMI<27.8 men/<27.3 women: ~78% “Obese”: BMI 27.8- <31.1 men/27.3- <32.3 women: ~16% “Severe obesity”: BMI ≥ 31.1 men/≥32.3 women ~7% | normotensive | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
1937662 | Ford 1991 | Dietary calcium intake | nd, not referenced | nd, not referenced | nd, not referenced | NA | NA | | NA | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
1937662 | Ford 1991 | 1° | Hypertension | SBP≥160 mm Hg or DBP ≥95 mm Hg or taking antihypertensive

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
1937662 | Ford 1991 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes | Caloric intake
1937662 | Ford 1991 | Demographics (e.g., age, gender, race, education)? | Yes | Age (subanalyses by race, sex)
1937662 | Ford 1991 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No
1937662 | Ford 1991 | Medical conditions
1937662 | Ford 1991 | Medication
1937662 | Ford 1991 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
1937662 | Ford 1991 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | No
1937662 | Ford 1991 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Follow-up | Mean Ca level/dose | No. of Cases (Event) * | Total N | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups *** | P for trend ****
1937662 | Ford 1991 | Incident HTN, white men | Quartile 1 | 10 y | <343.75 mg/day | 47 (22%) | ~215 | Adjusted | OR | 1.0 | --
| | | Quartile 2 | | 343.76–591.11 | 78 (20%) | ~382 | | | 0.91 | 0.60, 1.38 | NS
| | | Quartile 3 | | 591.12–953.77 | 104 (23%) | ~448 | | | 1.09 | 0.73, 1.63 | NS
| | | Quartile 4 | | >953.77 | 131 (20%) | ~662 | | | 0.96 | 0.64, 1.45 | NS
| | Incident HTN, white women | Quartile 1 | 10 y | <343.75 mg/day | 186 (22%) | ~865 | Adjusted | OR | 1.0 | --
| | | Quartile 2 | | 343.76–591.11 | 183 (23%) | ~806 | | | 1.11 | 0.87, 1.43 | NS
| | | Quartile 3 | | 591.12–953.77 | 172 (22%) | ~775 | | | 1.17 | 0.90, 1.51 | NS
| | | Quartile 4 | | >953.77 | 104 (17%) | ~619 | | | 1.01 | 0.74, 1.38 | NS
| | Incident HTN, black men | Quartile 1 | 10 y | <343.75 mg/day | 20 (42%) | ~48 | Adjusted | OR | 1.0 | --
| | | Quartile 2 | | 343.76–591.11 | 17 (38%) | ~45 | | | 0.68 | 0.28, 1.65 | NS
| | | Quartile 3 | | 591.12–953.77 | 18 (32%) | ~56 | | | 0.54 | 0.22, 1.33 | NS
| | | Quartile 4 | | >953.77 | 9 (27%) | ~34 | | | 0.35 | 0.11, 1.13 | .08
| | Incident HTN, black women | Quartile 1 | 10 y | <343.75 mg/day | 94 (42%) | ~225 | Adjusted | OR | 1.0 | --
| | | Quartile 2 | | 343.76–591.11 | 35 (29%) | ~120 | | | 0.61 | 0.37, 1.01 | .053
| | | Quartile 3 | | 591.12–953.77 | 31 (42%) | ~74 | | | 1.11 | 0.62, 2.01 | NS
| | | Quartile 4 | | >953.77 | 11 (30%) | ~37 | | | 0.77 | 0.33, 1.81 | NS

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
1937662 | Ford 1991 | a) Eligibility criteria clear? (y/n) | No | a) Exposure assessor blinded to outcome info? (y/n) | nd | a) Method reported? (y/n) | No | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories(eg quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | Yes | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Yes | a) Clear definition of outcome, including time of ascertainment? (y/n) | Yes | a) Prospective collection of data? (y/n) | Yes
1937662 | Ford 1991 | b) Sampling of population random or consecutive? (y/n) | Yes | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | No | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories(eg quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | Yes | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Yes | b) Loss to follow-up<20%? (y/n) | No | b) Analysis was planned when cohort was formed? (y/n) | Unclear
1937662 | Ford 1991 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | No | | | | | b) Justification of final adjusted model selection? (y/n) | No | c) Do the authors specify a primary outcome? (y/n) | Yes | c) Justification of sample size (includes sample size calculations)? (y/n) | No
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Very unclear reporting, particularly of numbers of subjects analyzed. Different methods used in different analyses without justification. Inadequate adjustment in primary model. >20% without sufficient data to include in analyses. Outdated definition of HTN.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Forman 2007

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17372031 | Forman 2007 | Cohort study | -participant of HPFS or NHS who submitted blood samples and had 25(OH)D measured | -Cases from case-control studies derived from HPFS and NHS except from the nested case- control study of colon polyps in the NHS, from which both cases and controls were included. -prevalent HTN at the time of blood collection | NHS: 1990–1998 HPFS: 1994–2002 | Health Professionals’ Follow-up Study (HPFS) and Nurses’ Health Study (NHS) | AHA | MB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
17372031 | Forman2007 | Cohort study | various | 1811 (613 men, 1198 women) | 1811 | Men: 65± 8 years Women: 57 ± 7 years | nd | 34% | - 95% of men and 85% of women were white | BMI ~ 25 ± 4 | nd | Low vit D intake in part of cohort

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
17372031 | Forman2007 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | 25(OH)D measured in several batches using RIA | Yes – coeff of variation ranged from 5.4% to 8.7% | nd | nd | nd
| | Dietary calcium intake

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17372031 | Forman 2007 | 1° (for this post hoc analysis) | Incident HTN | Subject reporting that their physician made a dx of HTN since preceding questionnaire (biennial questionnaires administered in both NHS and HPFS)

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17372031 | Forman 2007 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
17372031 | Forman 2007 | Demographics (e.g., age, gender, race, education)? | Yes | Age and race were included in all models
17372031 | Forman 2007 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI was included in all models
17372031 | Forman 2007 | Medical conditions
17372031 | Forman 2007 | Medication
17372031 | Forman 2007 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
17372031 | Forman 2007 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | Physical activity was included in all models
17372031 | Forman 2007 | Other | | Family hx of HTN, smoking status, menopausal status, season of blood draw, and intakes of vit D, EtOH, folate, Na, K, Ca, and Mg were tested individually and kept in model only if their inclusion changed the RR for 25(OH)D level by > 10%. Only menopausal status altered the effect estimate for < 15 ng/mL by > 10% and was maintained in final multivariable models.

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories | Mean Vit D level | No. of Cases (Event) * | Total N ** | Crude or Adjusted analysis? | Outcome Metric | Outcome effect size | CI ** | P between groups *** | P for trend ****
17372031 | Forman 2007 | Incident HTN | &bshade;25(OH)D ≥ 30 ng/mL (♂) | ≥ 30 ng/mL | 22 | 233 | Adjusted | &gshade;4-year RR | 1.0 (reference)
| | | &bshade;25(OH)D between 15 and 29 ng/mL (♂) | 15 and 29 | 33 | 347 | Adjusted | &gshade;4-year RR | 1.12 | 0.51– 2.48 | NS
| | | &bshade;25(OH)D < 15 ng/mL (♂) | < 15 | 6 | 33 | Adjusted | &gshade;4-year RR | 6.13 | 1.00– 37.8 | .05
| | | &bshade; | | | | | &gshade;
| | | &bshade;25(OH)D ≥ 15 ng/mL (♂) * | ≥ 15 ng/mL | 55 | 580 | Adjusted | &gshade;4-year RR | 1.0 (reference)
| | | &bshade;25(OH)D < 15 ng/mL (♂) * | < 15 | 6 | 33 | Adjusted | &gshade;4-year RR | 5.68 | 1.01–32.3 | <.05
| | | &bshade;25(OH)D ≥ 30 ng/mL (♂) | ≥ 30 ng/mL | nd | 233 | Adjusted | &yshade;8-year RR | 1.0 (reference)
| | | &bshade;25(OH)D < 15 ng/mL (♂) | < 15 | 9 | 33 | Adjusted | &yshade;8-year RR | 3.53 | 1.02–12.3 | < .05
| | | &bshade; | | | | | &yshade;
| | | &bshade;25(OH)D ≥ 15 ng/mL (♂) * | ≥ 15 ng/mL | 124 | 580 | Adjusted | &yshade;8-year RR | 1.0 (reference)
| | | &bshade;25(OH)D < 15 ng/mL (♂) * | < 15 | 9 | 33 | Adjusted | &yshade;8-year RR | 3.03 | 0.94– 9.76 | NS
| | | &pshade;25(OH)D ≥ 30 ng/mL (♀) | ≥ 30 ng/mL | 58 | nd | Adjusted | &gshade;4-year RR | 1.0 (reference)
| | | &pshade;25(OH)D between 15 and 29 ng/mL (♀) | 15 and 29 | 60 | nd | Adjusted | &gshade;4-year RR | 0.85 | 0.53– 1.34 | NS
| | | &pshade;25(OH)D < 15 ng/mL (♀) | < 15 | 11 | nd | Adjusted | &gshade;4-year RR | 2.67 | 1.05– 6.79 | < .05
| | | &pshade; | | | | | &gshade;
| | | &pshade;25(OH)D ≥ 15 ng/mL (♀) * | ≥ 15 ng/mL | 118 | nd | Adjusted | &gshade;4-year RR | 1.0 (reference)
| | | &pshade;25(OH)D < 15 ng/mL (♀) * | < 15 | 11 | nd | Adjusted | &gshade;4-year RR | 2.98 | 1.24– 7.20 | <.05
| | | &pshade;25(OH)D ≥ 30 ng/mL (♀) | ≥ 30 ng/mL | nd | nd | Adjusted | &yshade;8-year RR | 1.0 (reference)
| | | &pshade;25(OH)D < 15 ng/mL (♀) | < 15 | 20 | nd | Adjusted | &yshade;8-year RR | 1.70 | 0.92– 3.16 | NS
| | | &pshade; | | | | | &yshade;
| | | &pshade;25(OH)D ≥ 15 ng/mL (♀) * | ≥ 15 ng/mL | 254 | nd | Adjusted | &yshade;8-year RR | 1.0 (reference)
| | | &pshade;25(OH)D < 15 ng/mL (♀) * | < 15 | 20 | nd | Adjusted | &yshade;8-year RR | 1.42 | 0.79– 2.56 | NS

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

* Versus ≥ 15 ng/mL. Separate analysis from tertiles analysis

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
17372031 | Forman 2007 | Incident HTN | HPFS and NHS data were combined to compute a pooled result using random-effects model. Those with vit D levels < 15 ng/mL compared to those with levels ≥ 30 ng/mL had a 4-year RR of 3.18 (95% CI: 1.39 – 7.29), p<.05

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
17372031 | Forman 2007 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | Y | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | Y | a) Level of the exposure in comparative categories (eg quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounder s (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment ? (y/n) | N | a) Prospective collection of data? (y/n) | Y
17372031 | Forman 2007 | b) Sampling of population random or consecutive ? (y/n) | N | b) Outcome assessor blinded to exposure measurement ? (y/n) | Y | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | N | a) Level of the exposure in comparative categories (eg quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounder s (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
17372031 | Forman 2007 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Y | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | Y | c)Justification of sample size (includes sample size calculations) ? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): Time from sample collection to analysis not reported, no clear definition of outcome, food composition database not reported, no sample size calculations. | | | | | | | Data incomplete (formatting error in the table); potentially incomplete definition of outcome (no BP measurement). Small subset of all potentially available participants. Outcome did not include BP measurements.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Forman 2008

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
18838623 | Forman 2008 | Case- cohort study | Fasting for ≥ 8 hours; no diagnosis of hypertension; no use of antihypertensive medications; no diagnosis of cancer (except nonmelanoma skin cancer); no diagnosis of either coronary heart disease or diabetes; and BMI < 30 kg/m ^ 2 ^ | nd | 1989 | Nurses’ Health Study 2 | American Heart Association & National Institutes of Health | JHL

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat...cetc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake...etc.)
18838623 | Forman 2008 | Case- cohort study | US | 116,671 Female registered nurses joined the prospective cohort study in 1989, 29616 subjects contributed blood samples 1997–1999, 750 cases and 750 controls selected. | 742 cases and 742 controls | 43 (nd) | 40–46 | 0 | nd | BMI 24.1 | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed information as possible on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data…etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
18838623 | Forman 2008 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | Enzyme immunoassay | Y, coefficient variation=3.2% | nd | nd | 26.6 ng/mL
18838623 | Forman 2008 | Dietary calcium intake | nd | nd | nd | nd | nd | | nd | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
18838623 | Forman 2008 | Primary | Hypertension | Self-reported by the health professionals on biennial questionnaires (obtained medical records from a subset of randomly selected NHS 2 participants to validate hypertension, sensitivity 94%, specificity 85%)

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
18838623 | Forman 2008 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes | Ca, phosphorus, uric acid
18838623 | Forman 2008 | Demographics (e.g., age, gender, race, education)? | Yes * | Age ** , race **
18838623 | Forman 2008 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes * | BMI
18838623 | Forman 2008 | Medical conditions | Yes | Family history of hypertension
18838623 | Forman 2008 | Medication | Yes | Oral contraceptive use, creatinine
18838623 | Forman 2008 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
18838623 | Forman 2008 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes * | Physical activity
18838623 | Forman 2008 | Other | Yes | Date of blood sample collection ** , day of menstrual cycle ** , time of day of the blood collection ** , PTH

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

** Matching factors

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | Result | 95% CI | P btw
18838623 | Forman 2008 | Hypertension | < 30.0 | | 520 | 975 | OR | 1.64 | 1.29, 2.10 | nd | 1.47 | 1.10, 1.97 | nd
18838623 | Forman 2008 | Hypertension | ≥ 30.0 | | 222 | 509 | OR | 1.64 | 1.29, 2.10 | nd | 1.47 | 1.10, 1.97 | nd

* Example: OR Ca/placebo

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | Total N ** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups *** | P for trend ****
18838623 | Forman 2008 | Hypertension | Quartile 1 | ng/mL 37.9 ***** | | 151 | 369 | | Adjusted | OR | 1.0 | | | 0.01
| | | Quartile 2 | 29.2 | | 195 | 374 | | Adjusted | | 1.52 | 1.06, 2.18
| | | Quartile 3 | 23.8 | | 188 | 370 | | Adjusted | | 1.55 | 1.07, 2.23
| | | Quartile 4 | 16.7 | | 208 | 371 | | Adjusted | | 1.66 | 1.11, 2.48

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

***** median vitD level

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
18838623 | Forman 2008 | a) Eligibility criteria clear? (y/n) | y | a) Exposure assessor blinded to outcome info? (y/n) | n | a) Method reported? (y/n) | n | a) One of the prespecified methods *** was used? (y/n) | y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | a) Clear definition of outcome, including time of ascertainment? (y/n) | n | a) Prospective collection of data? (y/n) | y
18838623 | Forman 2008 | b) Sampling of population random or consecutive? (y/n) | y | b) Outcome assessor blinded to exposure measurement? (y/n) | n | b) Food composition database or suppl composition reported? (y/n) | n | Time from sample collection to sample analysis reported? (y/n) | n | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | b) Loss to follow-up <20%? (y/n) | n | b) Analysis was planned when cohort was formed? (y/n) | n
18838623 | Forman 2008 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | NA | | | | | b) Justification of final adjusted model selection? (y/n) | y | c) Do the authors specify a primary outcome? (y/n) | y | c) Justification of sample size (includes sample size calculations)? (y/n) | n
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): . | | | | | | | Relied on self-reported hypertension, insufficient power to examine the association between plasma 25(OH)D levels and incident hypertension

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Freedman 2007

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17971526 | Freedman 2007 | Cohort study | - Noninstitutionalized US population, age 17 y or older who completed physical examination (n=17,705) | - No 25(OH)D measurement (n=875); - Unknown mortality status (n=11); - Missing birthdate (n=1) | 1988–1994 | NHANES III | NIH/NCI, USPHS/DHHS | TTe

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location(e.g., City and Country, latitude) | N enrolled | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake…etc.)
17971526 | Freedman 2007 | Cohort study | US Mean latitude=38.3N | 16818 | 16818 | 44.0 (nd) | nd | 45.4 | - Non- Hispanic white: 71.2; - Non- Hispanic black: 14.1; - Mexican American: 5.8; - Other: 8.9 | BMI=26.7 kg/m ^ 2 ^ %body fat=23.4 | nd | Vit D: 4.7 mcg/d Ca: 811.8 mg/d

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Background exposure data
17971526 | Freedman 2007 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | RIA kit | The mean coefficient of variation:; - 17.6% (range 10–25%) for lower 25(OH)D values (20–62.5 nmol/L); - 15% (range12–18%) for higher values (85–147.5 nmol/L) | Nd (~7 to ~13 y) (follow-up of the entire cohort 146578 person- years) | Vit D intake: 4.7 mcg/d
17971526 | Freedman 2007 | Dietary calcium intake | 24HR | USDA food composition database | nd | nd | nd | | Ca intake: 811.8 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17971526 | Freedman 2007 | Primary | Cancer mortality | Based on ICD-10 codes ^ # ^
17971526 | Freedman 2007 | Secondary | Lung cancer mortality | Based on ICD-10 codes ^ # ^
17971526 | Freedman 2007 | Secondary | Digestive cancer mortality | Based on ICD-10 codes ^ # ^
17971526 | Freedman 2007 | Secondary | Breast cancer mortality | Based on ICD-10 codes ^ # ^
17971526 | Freedman 2007 | Secondary | Prostate cancer mortality | Based on ICD-10 codes ^ # ^
17971526 | Freedman 2007 | Secondary | Non-Hodgkin’s lymphoma/leukemia mortality | Based on ICD-10 codes ^ # ^
17971526 | Freedman 2007 | Secondary | Colorectal cancer mortality | Based on ICD-10 codes ^ # ^
17971526 | Freedman 2007 | Secondary | Other cancers mortality | Based on ICD-10 codes ^ # ^

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

# Reported ICD-10 codes include: C33 – C34 (lung, trachea, and bronchus); C18 – C21 (colon, rectum, and anus); C15, C16, C22, C25 (other digestive system, i.e., esophagus, stomach, liver, pancreatic cancer); C50 (breast); C61 (prostate); C82 – C85, C91 – C95 (non-Hodgkin lymphoma/leukemia); and C00 – C14, C17, C23 – C24, C26 – C32, C37 – C41, C43 – C49, C51 – C52, C54 – C60, C62 – C65, C67 – C80, C88, C90, C97 (other cancers, including buccal, larynx, melanoma, gynecological sites, kidney, bladder, brain, multiple myeloma).

Note: these are based on a death registry or a cancer database. Cases were not verified with medical records or pathology reports.

** Must explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17971526 | Freedman 2007 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes (calcium intake and serum retinol level) | Final model includes: sex, race/ethnicity, and smoking pattern
17971526 | Freedman 2007 | Demographics (e.g., age, gender, race, education)? | Yes (sex, race/ethnicity, and education)
17971526 | Freedman 2007 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes (BMI and total body fat)
17971526 | Freedman 2007 | Medical conditions | Yes (disease history)
17971526 | Freedman 2007 | Medication | No
17971526 | Freedman 2007 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | Yes (season and location/latitude)
17971526 | Freedman 2007 | Smoking and other life styles variables | Yes (smoking pattern) | Never, former, current (<20 pack-y), current (20 or more pack-y), current (unknown pack-y)
17971526 | Freedman 2007 | Other | Levels of physical activity

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

Final model includes: sex, race/ethnicity, and smoking pattern

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level (nmol/L) | Mean Ca level/dose | No. of Cases (Event) * | Total N ** | Mean follow- up period, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/ ** | P between groups *** | P for trend *** *
17971526 | Freedman 2007 | Cancer Mortality | 6-Q1 | <50 | nd | 175 | 5744 | 105 | Adjusted | HR | reference | - | nd | 0.65
17971526 | Freedman 2007 | Cancer Mortality | 6-Q2 | 50 to <62.5 | nd | 103 | 3143 | 105 | | HR | 1.22 | 0.91–1.64 | nd | 0.65
17971526 | Freedman 2007 | Cancer Mortality | 6-Q3 | 62.5 to <80 | nd | 117 | 3713 | 105 | | HR | 1.02 | 0.69–1.50 | nd | 0.65
17971526 | Freedman 2007 | Cancer Mortality | 6-Q4 | 80 to <100 | nd | 80 | 4218 | 105 | | HR | 1.00 | 0.71–1.40 | nd | 0.65
17971526 | Freedman 2007 | Cancer Mortality | 6-Q5 | 100 to <120 | nd | 41 | 4218 | 105 | | HR | 0.92 | 0.58–1.46 | nd | 0.65
17971526 | Freedman 2007 | Cancer Mortality | 6-Q6 | 120 or over | nd | 20 | 4218 | 105 | | HR | 1.49 | 0.85–2.64 | nd | 0.65
17971526 | Freedman 2007 | Lung Cancer Mortality | 4-Q1 | <50 | nd | 57 | 5744 | 105 | Adjusted | HR | reference | - | nd | 0.41
17971526 | Freedman 2007 | Lung Cancer Mortality | 4-Q2 | 50 to <80 | nd | 51 | 6856 | 105 | | HR | 0.78 | 0.50–1.22 | nd | 0.41
17971526 | Freedman 2007 | Lung Cancer Mortality | 4-Q3 | 80 to <100 | nd | 23 | 4218 | 105 | | HR | 0.65 | 0.36–1.18 | nd | 0.41
17971526 | Freedman 2007 | Lung Cancer Mortality | 4-Q4 | 100 or over | nd | 22 | 4218 | 105 | | HR | 1.14 | 0.60–2.18 | nd | 0.41
17971526 | Freedman 2007 | Digestive Cancer Mortality | 2-Q1 | <62.5 | nd | 34 | Nd | 105 | Adjusted | HR | reference | - | nd | 0.18
17971526 | Freedman 2007 | Digestive Cancer Mortality | 2-Q2 | 62.5 or over | nd | 37 | Nd | 105 | | HR | 1.42 | 0.73–1.76 | nd | 0.18
17971526 | Freedman 2007 | Breast Cancer Mortality | 2-Q1 | <62.5 | nd | 20 | Nd | 105 | Adjusted | HR | reference | - | nd | 0.76
17971526 | Freedman 2007 | Breast Cancer Mortality | 2-Q2 | 62.5 or over | nd | 8 | Nd | 105 | | HR | 0.28 | 0.08–0.93 | nd | 0.76
17971526 | Freedman 2007 | Prostate Cancer Mortality | 2-Q1 | <62.5 | nd | 22 | nd | 105 | Adjusted | RR | reference | - | nd | 0.95
17971526 | Freedman 2007 | Prostate Cancer Mortality | 2-Q2 | 62.5 | nd | 25 | nd | 105 | | RR | 0.91 | 0.39–2.14 | nd | 0.95
17971526 | Freedman 2007 | Non-Hodgkin’s lymphoma or leukemia Mortality | 2-Q1 | <62.5 | nd | 16 | nd | 105 | Adjusted | HR | reference | - | nd | 0.96
17971526 | Freedman 2007 | Non-Hodgkin’s lymphoma or leukemia Mortality | 2-Q2 | ≥62.5 or over | nd | 24 | nd | 105 | | HR | 1.34 | 0.62–2.91 | nd | 0.96
17971526 | Freedman 2007 | Colorectal Cancer Mortality | 3-Q1 | <50 | nd | 28 | nd | 105 | Adjusted | HR | reference | - | nd | 0.02
17971526 | Freedman 2007 | Colorectal Cancer Mortality | 3-Q2 | 50 to <80 | nd | 24 | nd | 105 | | HR | 0.44 | 0.20–0.95 | nd | 0.02
17971526 | Freedman 2007 | Colorectal Cancer Mortality | 3-Q3 | 80 or over | nd | 14 | nd | 105 | | HR | 0.28 | 0.11–0.68 | nd | 0.02
17971526 | Freedman 2007 | Other Cancers Mortality | 3-Q1 | <50 | nd | 38 | nd | 105 | Adjusted | HR | reference | - | nd | 0.84
17971526 | Freedman 2007 | Other Cancers Mortality | 3-Q2 | 50 to <80 | nd | 60 | nd | 105 | | HR | 1.83 | 0.93–3.61 | nd | 0.84
17971526 | Freedman 2007 | Other Cancers Mortality | 3-Q3 | 80 or over | nd | 32 | nd | 105 | | HR | 1.86 | 0.75–4.63 | nd | 0.84

Duplicate one row per exposure category or intervention group. Please write “nd” if there was no data reported. DO NOT LEAVE BLANK.

* Please choose one and delete the others

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

≥2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level (nmol/L) | Mean Ca level/dose | No. of Cases (Event)* | Total N** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/** | P between groups*** | P for trend****
17971526 | Freedman 2007 | Cancer Mortality (Winter/lower latitude) | 5-Q1 | <50 | nd | 74 | nd | Adjusted | HR | reference | - | Interaction (between winter/lower vs. summer/higher subgroups) P=0.36 | 0.65
17971526 | Freedman 2007 | Cancer Mortality (Winter/lower latitude) | 5-Q2 | 50 to <62.5 | nd | 37 | nd | Adjusted | HR | 1.02 | 0.59–1.76 | Interaction (between winter/lower vs. summer/higher subgroups) P=0.36 | 0.65
17971526 | Freedman 2007 | Cancer Mortality (Winter/lower latitude) | 5-Q3 | 62.5 to <80 | nd | 42 | nd | Adjusted | HR | 1.16 | 0.52–2.56 | Interaction (between winter/lower vs. summer/higher subgroups) P=0.36 | 0.65
17971526 | Freedman 2007 | Cancer Mortality (Winter/lower latitude) | 5-Q4 | 80 to<100 | nd | 30 | nd | Adjusted | HR | 0.95 | 0.51–1.79 | Interaction (between winter/lower vs. summer/higher subgroups) P=0.36 | 0.65
17971526 | Freedman 2007 | Cancer Mortality (Winter/lower latitude) | 5-Q5 | 100 or over | nd | 23 | nd | Adjusted | HR | 1.08 | 0.54–2.16 | Interaction (between winter/lower vs. summer/higher subgroups) P=0.36 | 0.65
17971526 | Freedman 2007 | Cancer Mortality (Summer/higher latitude) | 5-Q1 | <50 | nd | 101 | Nd | Adjusted | HR | reference | - | Interaction (between winter/lower vs. summer/higher subgroups) P=0.36 | 0.95
17971526 | Freedman 2007 | Cancer Mortality (Summer/higher latitude) | 5-Q2 | 50 to<62.5 | nd | 66 | Nd | Adjusted | HR | 1.29 | 0.90–1.85 | Interaction (between winter/lower vs. summer/higher subgroups) P=0.36 | 0.95
17971526 | Freedman 2007 | Cancer Mortality (Summer/higher latitude) | 5-Q3 | 62.5 to <80 | nd | 75 | Nd | Adjusted | HR | 0.96 | 0.65–1.41 | Interaction (between winter/lower vs. summer/higher subgroups) P=0.36 | 0.95
17971526 | Freedman 2007 | Cancer Mortality (Summer/higher latitude) | 5-Q4 | 80 to<100 | nd | 50 | Nd | Adjusted | HR | 1.00 | 0.65–1.54 | Interaction (between winter/lower vs. summer/higher subgroups) P=0.36 | 0.95
17971526 | Freedman 2007 | Cancer Mortality (Summer/higher latitude) | 5-Q5 | 100 or over | nd | 38 | Nd | Adjusted | HR | 1.09 | 0.66–1.81 | Interaction (between winter/lower vs. summer/higher subgroups) P=0.36 | 0.95
17971526 | Freedman 2007 | Cancer Mortality (Males) | 5-Q1 | <50 | nd | 88 | 1993 | Adjusted | HR | reference | - | Interaction (between winter/lower vs. summer/higher subgroups) P=0.70 | 0.08
17971526 | Freedman 2007 | Cancer Mortality (Males) | 5-Q2 | 50 to<62.5 | nd | 57 | 1461 | Adjusted | HR | 1.03 | 0.73–1.44 | Interaction (between winter/lower vs. summer/higher subgroups) P=0.70 | 0.08
17971526 | Freedman 2007 | Cancer Mortality (Males) | 5-Q3 | 62.5 to<80 | nd | 71 | 1845 | Adjusted | HR | 0.99 | 0.57–1.74 | Interaction (between winter/lower vs. summer/higher subgroups) P=0.70 | 0.08
17971526 | Freedman 2007 | Cancer Mortality (Males) | 5-Q4 | 80 to<100 | nd | 58 | 2333 | Adjusted | HR | 1.21 | 0.83–1.78 | Interaction (between winter/lower vs. summer/higher subgroups) P=0.70 | 0.08
17971526 | Freedman 2007 | Cancer Mortality (Males) | 5-Q5 | 100 or over | nd | 44 | 2333 | Adjusted | HR | 1.35 | 0.78–2.31 | Interaction (between winter/lower vs. summer/higher subgroups) P=0.70 | 0.08
17971526 | Freedman 2007 | Cancer Mortality (Females) | 5-Q1 | <50 | nd | 87 | 3751 | Adjusted | HR | reference | - | Interaction (between winter/lower vs. summer/higher subgroups) P=0.26 | 0.12
17971526 | Freedman 2007 | Cancer Mortality (Females) | 5-Q2 | 50 to<62.5 | nd | 46 | 1682 | Adjusted | HR | 1.40 | 0.94–2.08 | Interaction (between winter/lower vs. summer/higher subgroups) P=0.26 | 0.12
17971526 | Freedman 2007 | Cancer Mortality (Females) | 5-Q3 | 62.5 to<80 | nd | 46 | 1868 | Adjusted | HR | 1.02 | 0.62–1.67 | Interaction (between winter/lower vs. summer/higher subgroups) P=0.26 | 0.12
17971526 | Freedman 2007 | Cancer Mortality (Females) | 5-Q4 | 80 to<100 | nd | 22 | 1885 | Adjusted | HR | 0.72 | 0.40–1.26 | Interaction (between winter/lower vs. summer/higher subgroups) P=0.26 | 0.12
17971526 | Freedman 2007 | Cancer Mortality (Females) | 5-Q5 | 100 or over | nd | 17 | 1885 | Adjusted | HR | 0.78 | 0.40–1.53 | Interaction (between winter/lower vs. summer/higher subgroups) P=0.26 | 0.12
17971526 | Freedman 2007 | Cancer Mortality (Non- Hispanic white) | 4-Q1 | <50 | nd | 61 | 2964 | Adjusted | HR | reference | - | Interaction (between winter/lower vs. summer/higher subgroups) P=NS | 0.80
17971526 | Freedman 2007 | Cancer Mortality (Non- Hispanic white) | 4-Q2 | 50 to <80 | nd | 135 | 5206 | Adjusted | HR | 1.12 | 0.78–1.60 | Interaction (between winter/lower vs. summer/higher subgroups) P=NS | 0.80
17971526 | Freedman 2007 | Cancer Mortality (Non- Hispanic white) | 4-Q3 | 80 to<100 | nd | 57 | 3813 | Adjusted | HR | 1.02 | 0.66–1.56 | Interaction (between winter/lower vs. summer/higher subgroups) P=NS | 0.80
17971526 | Freedman 2007 | Cancer Mortality (Non- Hispanic white) | 4-Q4 | 100 or over | nd | 45 | | Adjusted | HR | 1.10 | 0.70–1.74 | Interaction (between winter/lower vs. summer/higher subgroups) P=NS | 0.80
17971526 | Freedman 2007 | Cancer Mortality (Non- Hispanic black) | 3-Q1 | <50 | nd | 80 | 1666 | Adjusted | HR | reference | - | Interaction (between winter/lower vs. summer/higher subgroups) P=NS | 0.14
17971526 | Freedman 2007 | Cancer Mortality (Non- Hispanic black) | 3-Q2 | 50 to <80 | nd | 42 | 609 | Adjusted | HR | 0.84 | 0.53–1.33 | Interaction (between winter/lower vs. summer/higher subgroups) P=NS | 0.14
17971526 | Freedman 2007 | Cancer Mortality (Non- Hispanic black) | 3-Q3 | 80 or over | nd | 22 | 101 | Adjusted | HR | 1.41 | 0.80–2.48 | Interaction (between winter/lower vs. summer/higher subgroups) P=NS | 0.14
17971526 | Freedman 2007 | Cancer Mortality (Mexican American) | 3-Q1 | <50 | Nd | 33 | 414 | Adjusted | HR | reference | - | Interaction (between winter/lower vs. summer/higher subgroups) P=NS | 0.37
17971526 | Freedman 2007 | Cancer Mortality (Mexican American) | 3-Q2 | 50 to <80 | Nd | 39 | 433 | Adjusted | HR | 0.89 | 0.42–1.87 | Interaction (between winter/lower vs. summer/higher subgroups) P=NS | 0.37
17971526 | Freedman 2007 | Cancer Mortality (Mexican American) | 3-Q3 | 80 or over | Nd | 15 | 122 | Adjusted | HR | 0.66 | 0.28–1.55 | Interaction (between winter/lower vs. summer/higher subgroups) P=NS | 0.37

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
17971526 | Freedman 2007 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | Nd | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | Y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
17971526 | Freedman 2007 | b) Sampling of population random or consecutive? (y/n) | nd | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | Nd
17971526 | Freedman 2007 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | n | | | | | b) Justification of final adjusted model selection? (y/n) | y | c) Do the authors specify a primary outcome? (y/n) | y | c) Justification of sample size (includes sample size calculations)? (y/n) | Nd
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): . | | | | | | | No details on enrollment and blinding assessment, some may have been excluded due to unavailability of data (e.g., blood sample), leading to the possibility of selection bias. NO adjustments on family history. How the diagnosis of cancer was verified was unclear.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Freedman 2008

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
18381472 | Freedman 2008 | Case-cohort study | Cases: All participants of Prostate, Lung, Colorectal, and Ovarian (PLCO) Cancer Screening Trial who provided baseline blood samples and background questionnaires, no history of breast cancer at baseline, but were diagnosed with an incident breast cancer between the date of the baseline blood collection (1993–2001) and June 30, 2005. Noncases: All participants of Prostate, Lung, Colorectal, and Ovarian (PLCO) Cancer Screening Trial who provided baseline blood samples and background questionnaires but had not reported a breast cancer as of June 30, 2005. | History of one of the four PLCO cancers, a recent history of screening procedures for one of the cancers, or were undergoing treatment for any cancer (other than nonmelanoma skin cancer ). | November 1993 and July 2001 | Prostate, Lung, Colorectal, and Ovarian (PLCO) Cancer Screening Trial | NIH | GR

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
18381472 | Freedman 2008 | Case- cohort study | 10 US centers 38 00 N | 1,005 cases and 1,005 non cases | 2010 | 66.5 | nd | 0 | ~90% Caucasian | ~21 | Ever smoker ~ 37–47% History of benign breast disease 16% – 31% HRT use 63%–78% Nulliparous 7% to 11% | Total calcium intake 1.1 to 1.7 g/d Supplement with vitD use 25% to 60%

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Background exposure data
18381472 | Freedman 2008 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | RIA | Coeff variation 8.2% for 25(OH)D 12.8% for 1,25(OH)2D | ~5y | FFQ for Ca and vit D
| | Dietary calcium intake

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
18381472 | Freedman 2008 | Primary outcome | Breast cancer risk | Incident breast cancer classified according to their behavior and histological patterns

UI | Author Year | Comments
18381472 | Freedman 2008 | Used quintiles to assess sensitivity of their findings to different analytical approaches. Data available for incident breast cancer risk after excluding first 2y of followup

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
18381472 | Freedman 2008 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
18381472 | Freedman 2008 | Demographics (e.g., age, gender, race, education)? | Yes, age at first birth, race
18381472 | Freedman 2008 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes - BMI
18381472 | Freedman 2008 | Medical conditions | Menopausal status, age at menarche, benign fibrocystic disease, family h/o breast cancer
18381472 | Freedman 2008 | Medication | Hormonal replacement
18381472 | Freedman 2008 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location)
18381472 | Freedman 2008 | Smoking and other life styles variables | Yes smoking status, alcohol intake
18381472 | Freedman 2008 | Other | Months of the blood draw, mammography, parity

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level | Followup | No. of Cases (Event) * | No. of Non- cases/Total N ** | Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
18381472 | Freedman 2008 | Incident breast cancer | Quintiles 1 <18.3 ng/mL | 25(OH)D | 12 y | 172 | 2010 | Y | RR | 1.0 | | | 0.81
18381472 | Freedman 2008 | Incident breast cancer | Quintiles 2 18.3-<23.5 ng/mL | 25(OH)D | 12 y | 188 | 2010 | Y | RR | 1.02 | 0.75–1.41
18381472 | Freedman 2008 | Incident breast cancer | Quintiles 3 23.5-<28.3 ng/mL | 25(OH)D | 12 y | 244 | 2010 | Y | RR | 1.36 | 0.99–1.87
18381472 | Freedman 2008 | Incident breast cancer | Quintiles 4 28.3-<33.7 ng/mL | 25(OH)D | 12 y | 205 | 2010 | Y | RR | 1.13 | 0.82–1.55
18381472 | Freedman 2008 | Incident breast cancer | Quintiles 5 ≥33.7 ng/mL | 25(OH)D | 12 y | 196 | 2010 | Y | RR | 1.04 | 0.75–1.45
18381472 | Freedman 2008 | Incident breast cancer | Quintiles 1 <28.2 pg/mL | 25(OH)2D | 12 y | 166 | 2010 | Y | RR | 1.0 | 1.0 | | 0.14
18381472 | Freedman 2008 | Incident breast cancer | Quintiles 2 28.2-<33.5 pg/mL | 25(OH)2D | 12 y | 186 | 2010 | Y | RR | 1.22 | 1.22
18381472 | Freedman 2008 | Incident breast cancer | Quintiles 3 33.5-<39 pg/mL | 25(OH)2D | 12 y | 206 | 2010 | Y | RR | 1.28 | 1.28
18381472 | Freedman 2008 | Incident breast cancer | Quintiles 4 39-<46.3 pg/mL | 25(OH)2D | 12 y | 234 | 2010 | Y | RR | 1.47 | 1.47
18381472 | Freedman 2008 | Incident breast cancer | Quintiles 5 ≥46.3 pg/mL | 25(OH)2D | 12 y | 212 | 2010 | Y | RR | 1.23 | 1.23

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | Outcome | | Design
18381472 | Freedman 2008 | a) Eligibility criteria clear? (y/n) | y | a) Exposure assessor blinded to outcome info? (y/n) | na | a) Method reported? (y/n) | y | a) One of the prespecified methods *** was used? (y/n) | y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | y
18381472 | Freedman 2008 | b) Sampling of population random or consecutive? (y/n) | y | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | n | Time from sample collection to sample analysis reported? (y/n) | y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | b) Loss to follow-up <20%? (y/n) | N | b) Analysis was planned when cohort was formed? (y/n) | y
18381472 | Freedman 2008 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | n | | | | | b) Justification of final adjusted model selection? (y/n) | c) Do the authors specify a primary outcome? (y/n) | y | c) Justification of sample size (includes sample size calculations)? (y/n) | n
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A | | | | | | | lacks data on exposure and dietary assessment

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Gaard 1996

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
9061275 | Gaard 1996 | Cohort study | - Attended NHSS health screening (n=62998); - Returned dietary assessment questionnaire (n=51982); - Answered 20 or more questions and had total energy intake of >501.9 kcal/d (n=51152) | Previous cancer (n=617) | 1977–1983 | NHSS | nd | TTE

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
9061275 | Gaard 1996 | Cohort study | Norway (Finnmark [69° 44’N], Sognog Fjordane [61° 04’N], Oppland [60° 47’N]) | 50535 | 50535 | 43 (nd) | 20–53(invited) | 49% (male and female were separately analyzed) | nd | nd | nd | Male; - Total energy: 2033.7 kcal/d; - Ca intake: 907 mg/d; - Total fat: 87.2 g/d; Female; - Total energy: 1343.5 kcal/d; - Ca intake: 637 mg/d; - Total fat: 55.4 g/d

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
9061275 | Gaard 1996 | Dietary calcium intake | FFQ | The Norwegian Food Composition table (Blaker et al. 1991) | Yes “acceptable” (reported separately in Loken et al 1987 in Finish) | na | na | | nd | 907 mg/d (M); 637 mg/d (F)

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
9061275 | Gaard 1996 | Primary (only reported outcome) | Colon cancer | Norwegian cancer registry (compulsory reporting of cancer cases by histopathology departments)

UI | Author Year | Comments
9061275 | Gaard 1996 | Rectal cancer not reported in this article

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
9061275 | Gaard 1996 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Energy
9061275 | Gaard 1996 | Demographics (e.g., age, gender, race, education)? | Yes (age [20–44/45–49/55-], attained age [-50/51–54/55-]) | Men and women were separately analyzed
9061275 | Gaard 1996 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes (BMI, height)
9061275 | Gaard 1996 | Medical conditions | No
9061275 | Gaard 1996 | Medication | No
9061275 | Gaard 1996 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | No
9061275 | Gaard 1996 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes (smoking [current/ex-/never])
9061275 | Gaard 1996 | Other | Nd

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean follow- up time, mo | Mean Ca level/dose | No. of Cases (Event) * | Person- years ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups *** | P for trend ****
Men
9061275 | Gaard 1996 | Colon cancer (total Ca [mg]) | Q1 | 134.4 | −758 | 22 | 73785 | adjusted | RR (OR?) | 1.00 | Ref | Nd | 0.15
| | | Q2 | 134.4 | 759–912 | 24 | 72101 | adjusted | RR (OR?) | 1.02 | 0.57–1.83 | Nd
| | | Q3 | 134.4 | 913–1066 | 24 | 71950 | adjusted | RR (OR?) | 1.04 | 0.58–1.86 | Nd
| | | Q4 | 134.4 | 1067- | 13 | 70992 | adjusted | RR (OR?) | 0.57 | 0.29–1.13 | nd
Women | | | | 134.4
9061275 | Gaard 1996 | Colon cancer (total Ca [mg]) | Q1 | 134.4 | -527 | 15 | 71563 | adjusted | RR (OR?) | 1.00 | Ref | Nd | 0.94
| | | Q2 | 134.4 | 528–628 | 20 | 70540 | Adjusted | RR (OR?) | 1.25 | 0.63–2.46 | Nd
| | | Q3 | 134.4 | 629–743 | 7 | 69896 | Adjusted | RR (OR?) | 0.46 | 0.19–1.12 | Nd
| | | Q4 | 134.4 | 744- | 18 | 69926 | adjusted | RR (OR?) | 1.20 | 0.60–2.39 | nd

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
9061275 | Gaard 1996 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | Nd | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories(eg quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
9061275 | Gaard 1996 | b) Sampling of population random or consecutive? (y/n) | n | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories(eg quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up<20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
9061275 | Gaard 1996 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | y | | | | | b) Justification of final adjusted model selection? (y/n) | n | c) Do the authors specify a primary outcome? (y/n) | N | c) Justification of sample size (includes sample size calculations)? (y/n) | n
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Post-hoc analysis of an existing cohort. Some limited reporting. Cases not confirmed by histology; a series of potential correlations are reported as outcomes; power calculation not reported; analyses of the whole sample is not provided (only per gender); consecutive sampling only for part of the population while random sampling for another part; blinding not reported

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Gale 2008

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17311057 | Gale 2008 | Cohort study | Caucasian women ≥16 y; singleton pregnancy <17 wk gestation | | 1991–92 | - | non-profit | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
17311057 | Gale 2008 | Cohort study | Southampton, UK | 466 | 440 | 26.3 (est.) | | 0 | Caucasians | prepregnancy wt: 59 Kg (est.) | | vit D intake (food & supplements): 2.9 μg in late pregnancy

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
17311057 | Gale 2008 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | RIA | y; intra and interassay CV <10%) | 5 y | not explicitly reported | UV-B exposure from 2974 (bottom quartile of 25 (OH)D) to 32017 (top quartile of 25 (OH)D) Wh/m2
| | Dietary calcium intake

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17311057 | Gale 2008 | primary | birth length
| | | birth weight
| | | 9 mo length
| | | 9 mo weight
| | | atopic eczema at 9 mo | modified UK Working Party Diagnostic Criteria, 1994

UI | Author Year | Comments
17311057 | Gale 2008 | Data from a longitudinal cohort of UK children whose mothers had taken part in a nutritional survey during pregnancy

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17311057 | Gale 2008 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
17311057 | Gale 2008 | Demographics (e.g., age, gender, race, education)? | Yes * | age
17311057 | Gale 2008 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no *
17311057 | Gale 2008 | Medical conditions | no
17311057 | Gale 2008 | Medication
17311057 | Gale 2008 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | Yes | UVB exposure
17311057 | Gale 2008 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no *
17311057 | Gale 2008 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level | Mean Ca level/dose | No. of Cases | Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
17311057 | Gale 2008 | atopic eczema at 9 mo | Quartile 1:<30 nmol/L | | | 9 | 440 | crude | OR | 1.0
| | | Quartile 2: 30–50 | | | 10 | 440 | | | 1.11 | 0.43–2.84
| | | Quartile 3: >50–75 | | | 15 | 440 | | | 1.75 | 0.73–4.17
| | | Quartile 4: >75 | | | 14 | 440 | | | 1.62 | 0.67–3.89

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

≥2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure Category/Intervention Group | Crude or Adjusted analysis? | Mean Follow-up (months) | No. Analyzed | Baseline | Baseline CI/SE/SD * | Final | Final SD * | Net difference *** | Net difference CI/SE/SD * | P between groups ***
17311057 | Gale 2008 | birth weight | Kg | Quartile 1:<30 nmol/L | crude | | | | | 3.38 | 0.46 | | | 0.247
| | | | Quartile 2: 30–50 | | | | | | 3.40 | 0.56
| | | | Quartile 3: >50–75 | | | | | | 3.49 | 1.57
| | | | Quartile 4: >75 | | | | | | 3.43 | 0.51
| | birth length | cm | Quartile 1:<30 nmol/L | crude | | | | | 50 | 1.83 | | | 0.150
| | | | Quartile 2: 30–50 | | | | | | 50 | 2.29
| | | | Quartile 3: >50–75 | | | | | | 50.5 | 2.25
| | | | Quartile 4: >75 | | | | | | 50.1 | 2.09
17311057 | Gale 2008 | 9 mo weight | Kg | Quartile 1:<30 nmol/L | crude | | | | | 9.10 | 1.07 | | | 0.873
| | | | Quartile 2: 30–50 | | | | | | 9.03 | 1.14
| | | | Quartile 3: >50–75 | | | | | | 9.24 | 1.34
| | | | Quartile 4: >75 | | | | | | 9.07 | 1.06
| | 9 mo length | cm | Quartile 1:<30 nmol/L | crude | | | | | 71.2 | 2.85 | | | 0.861
| | | | Quartile 2: 30–50 | | | | | | 71.4 | 2.60
| | | | Quartile 3: >50–75 | | | | | | 71.7 | 2.89
| | | | Quartile 4: >75 | | | | | | 71.1 | 2.67

Duplicate one row per exposure category or intervention group. Please write “nd” if there was no data reported. DO NOT LEAVE BLANK.

* Please choose one and delete the others

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−” sign: e.g. +2.8 or −2.8

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
17311057 | Gale 2008 | no adjustment for potential confounders like FH of atopy

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
17311057 | Gale 2008 | a) Eligibility criteria clear? (y/n) | n | a) Exposure assessor blinded to outcome info? (y/n) | n | a) Method reported? (y/n) | y | a) One of the prespecified methods *** was used? (y/n) | y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | n | a) Clear definition of outcome, including time of ascertainment? (y/n) | y | a) Prospective collection of data? (y/n) | y
17311057 | Gale 2008 | b) Sampling of population random or consecutive? (y/n) | nd | b) Outcome assessor blinded to exposure measurement? (y/n) | n | b) Food composition database or suppl composition reported? (y/n) | n | Time from sample collection to sample analysis reported? (y/n) | y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | n | b) Loss to follow-up <20%? (y/n) | y | b) Analysis was planned when cohort was formed? (y/n) | nd
17311057 | Gale 2008 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | n | | | | | b) Justification of final adjusted model selection? (y/n) | n | c) Do the authors specify a primary outcome? (y/n) | y | c) Justification of sample size (includes sample size calculations)? (y/n) | n
OVERALL Grade (A/B/C) | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | no adjustment for potential confounders

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Gann 1996

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
8850273 | Gann 1996 | Case-cohort study | US male physicians | Prior history of MI, stroke, TIA, unstable angina, cancer except for nonmelanoma skin cancer, current renal or liver disease, peptic ulcer or gout, contraindication to aspirin use, current use of aspirin, other platelet-active agents, or vitamin A supplements. | nd | Physicians’ Health Study (PHS) | NIH | KP/SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
8850273 | Gann 1996 | Case-cohort study | United States (multiple locations) | 22,071 in original cohort, 520 cases matched 1:2 with controls, 646 total with adequate exposure data | 232 cases and 414 controls | 62 yrs | 40–84 yrs at baseline | 100% | Nd | Nd | Nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
8850273 | Gann 1996 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | RIA for 25-D, radioreceptor assay using calf thymus receptor for 1,25-D | Y; CV = 8.1% for 25-D, 7.9% for 1,25-D | nd | 66.4% collected in fall | nd
| | Dietary calcium intake

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
8850273 | Gann 1996 | Nd | Prostate cancer | Medical records and pathology reports

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
8850273 | Gann 1996 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
8850273 | Gann 1996 | Demographics (e.g., age, gender, race, education)? | Yes | Age (match)
8850273 | Gann 1996 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no
8850273 | Gann 1996 | Medical conditions
8850273 | Gann 1996 | Medication
8850273 | Gann 1996 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | Season of blood collection (for 25-D)
8850273 | Gann 1996 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | Smoking (match)
8850273 | Gann 1996 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level | Mean Ca level/dose | No. of Cases (Event) * | No of Non-cases/Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups *** | P for trend ****
8850273 | Gann 1996 | Total prostate cancer | Quartile 1: 25-D 6.3–21.3 ng/mL | Nd | nd | Nd | Nd | adjusted | OR | 1.00 | nd | Nd | 0.82
| | | Quartile 2: 25-D 21.4–28.4 | Nd | Nd | Nd | Nd | | | 1.10 | Nd | Nd
| | | Quartile 3: 25-D 28.5–37.4 | Nd | Nd | Nd | Nd | | | 1.16 | Nd | Nd
| | | Quartile 4: 25-D 37.5–77.8 | nd | Nd | Nd | Nd | | | 0.92 | 0.56–1.50 | nd
| | Total prostate cancer | Quartile 1: 1,25-D 13.8–28.5 pg/mL | Nd | nd | Nd | Nd | adjusted | OR | 1.00 | nd | Nd | 0.50
| | | Quartile 2: 1,25-D 28.6–33.8 | Nd | Nd | Nd | Nd | | | 1.13 | Nd | Nd
| | | Quartile 3: 1,25-D 33.9–40.1 | Nd | Nd | Nd | Nd | | | 0.85 | Nd | Nd
| | | Quartile 4: 1,25-D 40.2–129.1 | nd | Nd | Nd | Nd | | | 0.88 | 0.53–1.45 | nd

Note: ORs are controlled for age and smoking by matching, 25-D is additionally adjusted for season of blood collection

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

MEAN DATA

THIS SHOULD ONLY APPLY TO CASE-COHORT STUDIES THAT COMPARE BASELINE VIT D/CA LEVELS BETWEEN CASES (WITH DISEASE) AND CONTROLS (WITHOUT DISEASE)

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Mean 25(OH)D Level | Vit D level CI/SE/SD* | Mean Ca intake or Ca balance | Ca CI/SE/SD* | P between groups
8850273 | Gann 1996 | Cases: | nd | crude | 232 | 29.3 | | | | 0.80
| | Control: | | | 414 | 28.5

Duplicate one table per outcome

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
8850273 | Gann 1996 | Total prostate cancer | Models adjusting for BMI, exercise, smoking, and alcohol produced nearly identical results, although they were not specifically listed.
| | Prostate cancer by age | Quartiles of 25-D and 1,25-D did not list ranges, CI for comparison of Quartile 4 to quartile one was given and was not significant for either ages >61 yrs or ≤61 yrs.

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | No. of Non-cases/Total N** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups*** | P for trend****
8850273 | Gann 1996 | Total prostate cancer; age ≤ 61 y | Quartile 1: 25-D 6.3–21.3 ng/mL | Nd | nd | Nd | Nd | adjusted | OR | 1.00 | nd | Nd | nd
| | | Quartile 2: 25-D 21.4–28.4 | Nd | Nd | Nd | Nd | | | 1.19 | Nd | Nd
| | | Quartile 3: 25-D 28.5–37.4 | Nd | Nd | Nd | Nd | | | 1.75 | Nd | Nd
| | | Quartile 4: 25-D 37.5–77.8 | nd | Nd | Nd | Nd | | | 1.48 | 0.73–2.98 | nd
| | Total prostate cancer; age >61 y | Quartile 1: 25-D 6.3–21.3 ng/mL | Nd | nd | Nd | Nd | adjusted | OR | 1.00 | nd | Nd | nd
| | | Quartile 2: 25-D 21.4–28.4 | Nd | Nd | Nd | Nd | | | 1.00 | Nd | Nd
| | | Quartile 3: 25-D 28.5–37.4 | Nd | Nd | Nd | Nd | | | 0.82 | Nd | Nd
| | | Quartile 4: 25-D 37.5–77.8 | nd | Nd | Nd | Nd | | | 0.76 | 0.39–1.47 | nd
| | Total prostate cancer; age ≤ 61 y | Quartile 1: 1,25-D 13.8–28.5 pg/mL | Nd | nd | Nd | Nd | adjusted | OR | 1.00 | nd | nd | nd
| | | Quartile 2: 1,25-D 28.6–33.8 | Nd | Nd | Nd | Nd | | | 1.61 | nd | nd
| | | Quartile 3: 1,25-D 33.9–40.1 | Nd | Nd | Nd | Nd | | | 1.10 | nd | nd
| | | Quartile 4: 1,25-D 40.2–129.1 | nd | Nd | Nd | Nd | | | 0.93 | 0.44–1.95 | nd
| | Total prostate cancer; age >61 y | Quartile 1: 1,25-D 13.8–28.5 pg/mL | Nd | nd | Nd | Nd | adjusted | OR | 1.00 | nd | Nd | nd
| | | Quartile 2: 1,25-D 28.6–33.8 | Nd | Nd | Nd | Nd | | | 0.81 | Nd | Nd
| | | Quartile 3: 1,25-D 33.9–40.1 | Nd | Nd | Nd | Nd | | | 0.65 | Nd | Nd
| | | Quartile 4: 1,25-D 40.2–129.1 | nd | Nd | Nd | Nd | | | 0.82 | 0.39–1.47 | nd

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
8850273 | Gann 1996 | a) Eligibility criteria clear? (y/n) | y | a) Exposure assessor blinded to outcome info? (y/n) | y | a) Method reported? (y/n) | na | a) One of the prespecified methods *** was used? (y/n) | y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
8850273 | Gann 1996 | b) Sampling of population random or consecutive? (y/n) | na | b) Outcome assessor blinded to exposure measurement? (y/n) | na | b) Food composition database or suppl composition reported? (y/n) | na | Time from sample collection to sample analysis reported? (y/n) | n | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | b) Loss to follow-up <20%? (y/n) | NA | b) Analysis was planned when cohort was formed? (y/n) | n
8850273 | Gann 1996 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | na | | | | | b) Justification of final adjusted model selection? (y/n) | n | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Less than half of physicians who were cases provided samples adequate for analysis. Results were not provided for fully adjusted model.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Garland 1985

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
2857364 | Garland 1985 | Cohort study | Randomly selected from the population of men aged 40–55 years who had been employed for at least 2 years at the Western Electric Company’s Hawthorne Works in Chicago | Age at first examination less than 40 y, vital status unknown at the twentieth anniversary, malignancy diagnosed before second examination, death before second examination, termination of employment with the company or transfer to another plant, withdrawal from the study, lack of information from the second examination with respect to diet or cigarette smoking | 1957–1958 | Western Electric Health Study | American heart association | JHL

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
2857364 | Garland 1985 | Cohort study | Chicago, US 41° N | 2107 | 1954 | 48.7 (4.4) | | 100 | 65% Americans of Germen, Polish, or Bohemian ancestry, most of others from the British Isles | BMI 25.5 | nd | Nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
2857364 | Garland 1985 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | nd | nd | nd | nd
2857364 | Garland 1985 | Dietary calcium intake | 28-day diet histories | Food composition table (Ref 2) | nd | nd | nd | | nd | mg/1000kcal Cancer: 316.7 No cancer: 326.7

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
2857364 | Garland 1985 | nd | Colorectal cancer | Medical and hospital records

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
2857364 | Garland 1985 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes (Dietary intake)
2857364 | Garland 1985 | Demographics (e.g., age, gender, race, education)? | Yes * - age
2857364 | Garland 1985 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes * - BMI
2857364 | Garland 1985 | Medical conditions
2857364 | Garland 1985 | Medication
2857364 | Garland 1985 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
2857364 | Garland 1985 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes (Cigarette consumption, ethanol consumption)
2857364 | Garland 1985 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
2857364 | Garland 1985 | Colorectal cancer | Ca (mg/1000kcal) – quartile 1 | | 102–241 | 19 | 488 | Adjusted for age | HR | nd | nd | | nd
| | | Ca (mg/1000kcal) - quartile 2 | | 242–306 | 12 | 489 | | HR | nd | nd
| | | Ca (mg/1000kcal) - quartile e 3 | | 307–383 | 12 | 489 | | HR | nd | nd
| | | Ca (mg/1000kcal) - quartile 4 | | 384–906 | 6 | 458 | | HR | nd | nd

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

MEAN DATA

THIS SHOULD ONLY APPLY TO CASE-COHORT STUDIES THAT COMPARE BASELINE VIT D/CA LEVELS BETWEEN CASES (WITH DISEASE) AND CONTROLS (WITHOUT DISEASE)

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Mean 25(OH)D Level | Vit D level CI/SE/SD* | Mean Ca intake or Ca balance | Ca CI/SE/SD* | P between groups
| | Cases: | 19 yr | | 49 | | | 289.9/1000kcal | nd | ≤ 0.05
| | Control: | 19 yr | | 1905 | | | nd | nd

Duplicate one table per outcome

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
2857364 | Garland 1985 | Results on the model with multiple factor adjustment are not shown; it is reported that these results were similar to the models (univariate and age adjustred) shown in the article Based on coefficient and SE, HR (95% CI) can be calculated: 1 (1–0.99) both for univariate and for age adjusted models (for calcium); however, p-values given are one-tailed, which may no longer be statistically significant if converted to two-tailed p-values (same applies for one way analysis)

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
2857364 | Garland 1985 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | n | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given y (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | N | a) Clear definition of outcome, including time of ascertainment? (y/n) | N | a) Prospective collection of data? (y/n) | y
2857364 | Garland 1985 | b) Sampling of population random or consecutive? (y/n) | y | b) Outcome assessor blinded to exposure measurement? (y/n) | Y | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given y (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | N | b) Loss to follow-up <20%? (y/n) | N | b) Analysis was planned when cohort was formed? (y/n) | N
2857364 | Garland 1985 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | N | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Validity of 28-day dietary histories was not examined; exposure assessor blinding not reported; power calculation not reported; use of one-tailed test for significance in Cox regression and in one way analysis (exact p-value not given); results poorly reported

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Garland 1989

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
2572900 | Garland 1989 | Case-cohort study | - Community volunteer cohort participants Cases: colon caner cases (ICD-8; - 153.0–153.8) diagnosed between 1/1/75 & 12/31/83; - Controls: 1:2 matching controls (by race, sex, age, month of blood draw, census registry status) | Cases:; - Non-white cases; - Previous cancer (excl. non-melanoma skin cancer) | 1974 (Sep-Nov) | nd | NCI, The Dairy Bureau of Canada, National Heart Lung and Blood Institute | JHL/TTE

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
2572900 | Garland 1989 | Case-cohort study | Washington county, Maryland (38° 42′) | Original Cohort (n=25620) Cases (N=34) Controls (N=67) | 101 | 62.8 (no SD) | nd | 49.5% | White: 100% | nd | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
2572900 | Garland 1989 | 25(OH)D | | | | HPLC and UV absorbance detection | Inter-assay coefficient of variation (CV) =7.6% | At least ~9 y (assuming last dx) max ~15 y | Aug-Nov | nd
2572900 | Garland 1989 | Dietary calcium intake | nd | nd | nd | nd | nd | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
2572900 | Garland 1989 | nd | Colon cancer | ICD-8 153.0–153.8 (probably registry data, unclear about confirmation by medical records/pathological reports or by other means)

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
2572900 | Garland 1989 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | | Matching factors: race, sex, age, month blood was taken
2572900 | Garland 1989 | Demographics (e.g., age, gender, race, education)? | Yes | Matching factors: race, sex, age, month blood was taken
2572900 | Garland 1989 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No | Matching factors: race, sex, age, month blood was taken
2572900 | Garland 1989 | Medical conditions | | Matching factors: race, sex, age, month blood was taken
2572900 | Garland 1989 | Medication | | Matching factors: race, sex, age, month blood was taken
2572900 | Garland 1989 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | Month blood was taken | Matching factors: race, sex, age, month blood was taken
2572900 | Garland 1989 | Smoking and other life styles variables | No | Matching factors: race, sex, age, month blood was taken
2572900 | Garland 1989 | Other | | Matching factors: race, sex, age, month blood was taken

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non-cases ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
2572900 | Garland | Colon | 25(OH)D – quintile 1 | 4–19 | | 9 | 8 | Adjusted | OR | 1.0 (ref)
2572900 | Garland | Colon | 25(OH)D – quintile 2 | 20–26 | | 7 | 13 | Adjusted | | 0.48 | Nd
2572900 | Garland | Colon | 25(OH)D – quintile 3 | 27–32 | | 5 | 18 | Adjusted | | 0.25 | Nd | ≤0.05 (vs. Q1)
2572900 | Garland | Colon | 25(OH)D – quintile 4 | 33–41 | | 4 | 17 | Adjusted | | 0.21 | Nd | ≤0.05 (vs. Q1)
2572900 | Garland | Colon | 25(OH)D – quintile 5 | 42–91 | | 9 | 11 | Adjusted | | 0.73 | Nd
2572900 | Garland 1989 | Colon cancer | 25(OH)D – group 1 | 0–29 | | | 42 ***** | Adjusted (matching) | OR | 1.0 (ref)
2572900 | Garland 1989 | Colon cancer | 25(OH)D – group 2 | ≥ 30 | | | 57 ***** | Adjusted (matching) | | 0.5 | Nd | 0.13
2572900 | Garland 1989 | Colon cancer | 25(OH)D – group 1 | 0–19 | | | 17 ***** | Adjusted (matching) | OR | 1.0 (ref)
2572900 | Garland 1989 | Colon cancer | 25(OH)D – group 2 | ≥20 | | | 82 ***** | Adjusted (matching) | | 0.3 | Nd | 0.05 (1-sided)

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

***** Total N

MEAN DATA

THIS SHOULD ONLY APPLY TO CASE-COHORT STUDIES THAT COMPARE BASELINE VIT D/CA LEVELS BETWEEN CASES (WITH DISEASE) AND CONTROLS (WITHOUT DISEASE)

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Mean 25(OH)D Level | Vit D level CI/SE/SD* | Mean Ca intake or Ca balance | Ca CI/SE/SD* | P between groups
2572900 | Garland 1989 | Cases: | 11 mo to ~9 y | Adjusted (matching) | 34 | 30.5 ng/ml | Nd | | | P=0.05
| | Control: | 11 mo to ~9 y | Adjusted (matching) | 67 | 33.3 ng/ml | Nd

Duplicate one table per outcome

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
2572900 | Garland 1989 | a) Eligibility criteria clear? (y/n) | N | a) Exposure assessor blinded to outcome info? (y/n) | ND | a) Method reported? (y/n) | NA | a) One of the prespecified methods *** was used? (y/n) | Y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | N | a) Prospective collection of data? (y/n) | Y
2572900 | Garland 1989 | b) Sampling of population random or consecutive? (y/n) | N | b) Outcome assessor blinded to exposure measurement? (y/n) | ND | b) Food composition database or suppl composition reported? (y/n) | NA | Time from sample collection to sample analysis reported? (y/n) | N | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | NA | b) Analysis was planned when cohort was formed? (y/n) | N
2572900 | Garland 1989 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | NA | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | N | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): . | | | | | | | Poor reporting, post-hoc analysis of a prospective cohort study, no controlling for family history of colon cancer

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Ghadirian 1995

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
7493659 | Ghadirian 1995 | RCT | Post- menopausal nuns ≥50 y | Acute illness, medical treatments that may affect blood pressure, lipids and other parameters, memory lapses, therapeutic diets, high anxiety | ≤1994 | none | Dairy Bureau | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
7493659 | Ghadirian 1995 | RCT | Montreal, Canada 45.7° | 265 | 158 | Maybe ~80 | 50–69: 25% ≥70: 75% | 0% | Probably almost all white | 59.7 Kg | Healthy | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
7493659 | Ghadirian 1995 | Dietary calcium intake | FFQ & 24 hr recall | Canadian Nutrient File | no | NA | NA | | nd | 776 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
7493659 | Ghadirian 1995 | Dairy diet | Regular food | Achieved 1242 mg/d (30 g dairy protein) | 4 wk | 3 meals
| | Dairy free diet | | Achieved 377 mg/day
Co-intervention(s) * :
Compliance/Adherence: | | | Non-compliant and those who provided incomplete data were excluded.

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
7493659 | Ghadirian 1995 | 2° | Weight | Kg
| | 2° | SBP/DBP

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder including matching factors) | Specific comments for confounders
7493659 | Ghadirian 1995 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
7493659 | Ghadirian 1995 | Demographics (e.g., age, gender, race, education)? | No
7493659 | Ghadirian 1995 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No (NA for weight analysis)
7493659 | Ghadirian 1995 | Medical conditions
7493659 | Ghadirian 1995 | Medication
7493659 | Ghadirian 1995 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
7493659 | Ghadirian 1995 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | No
7493659 | Ghadirian 1995 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline SD * | Final | Final SD * | Net difference | Net difference CI/SE/SD * | P between
7493659 | Ghadirian 1995 | Weight | Kg | Dairy diet | 1 | 81 | 59.84 | 11.33 | 59.94 | 11.37 | +0.5 | | NS (implied)
7493659 | Ghadirian 1995 | Weight | Kg | Dairy free diet | | 77 | 59.65 | 15.34 | 59.25 | 14.80
| | SBP | mm Hg | Dairy diet | 1 | 81 | 140.34 | 20.55 | 137.65 | 22.14 | −5.44 | | NS (implied)
| | SBP | mm Hg | Dairy free diet | | 77 | 131.71 | 23.91 | 134.46 | 21.31
| | DBP | mm Hg | Dairy diet | 1 | 81 | 81.17 | 9.87 | 73.39 | 10.67 | −2.19 | | NS (implied)
| | DBP | mm Hg | Dairy free diet | | 77 | 79.09 | 9.89 | 73.50 | 10.42

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
7493659 | Ghadirian 1995 | RCT | nd | nd | NA | No | No | No | No | No | No | C
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Poorly reported, poorly analyzed. Very high dropout rate.

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Giovannucci 2006 and Giovannucci 2007

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
16492906 and 17450530 | Giovannucci 2006 and Giovannucci 2007 *** | Cohort study | Male health professionals | -Cancer (except nonmelanoma skin cancer) -men who did not adequately complete SFFQ | 1986 – 2002 | Health Professionals Follow-up Study | NCI, NIH, NHLBI | KP/SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

*** note: data in this document is derived from Giovannucci 2006. Giovannucci 2007 contained no extra information, but slightly different numbers because of different included confounders.

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake...etc.)
16492906 | Giovannucci 2006 | Cohort study | United States (various) | 51,529 in original cohort | 47,750 | nd | 40–75 yrs at baseline | 100% | >91% Caucasian | nd | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
16492906 | Giovannucci 2006 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | 25(OH)D and 1,25(OH)D by RIA | Intrapair CV ranged from 5%–7% | nd | All samples drawn in 1993 to 1994 | NA
| | Dietary calcium intake | SFFQ | USDA | Yes: used a sample of 127 cohort members from Boston area. Total energy-adjusted Ca was 815±280 mg/d based on diet records and 839±346 mg/d based on SFFQ. Their correlation was 0.61 | None | NA | | NA | Nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
16492906 | Giovannucci 2006 | nd | Prostate cancer | Cases derived from self report, pathology reports, hospital records. T1a cancers excluded.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
16492906 | Giovannucci 2006 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Total calories, red meat, fish, α-linolenic acid, zinc supplements, tomato sauce
16492906 | Giovannucci 2006 | Demographics (e.g., age, gender, race, education)? | Yes | Age, race
16492906 | Giovannucci 2006 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI at age 21, height
16492906 | Giovannucci 2006 | Medical conditions | Family history of prostate cancer, history of diabetes
16492906 | Giovannucci 2006 | Medication
16492906 | Giovannucci 2006 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
16492906 | Giovannucci 2006 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | Cigarette pack years, vigorous physical activity level
16492906 | Giovannucci 2006 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non- cases/Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups *** | P for trend ****
16492906 | Giovannucci 2006 | Total prostate cancer | Total calcium <500 mg/d | nd | nd | 183 | Nd | adjusted | RR | 0.98 | 0.84–1.15 | | 0.10
| | | Total calcium = 50–49 mg/d | nd | nd | 1072 | Nd | | | 1 | Reference
| | | Total calcium = 75–99 mg/d | nd | nd | 1099 | Nd | | | 1.07 | 0.98–1.16
| | | Total calcium = 1,00–,499 mg/d | nd | nd | 898 | Nd | | | 1.03 | 0.94–1.14
| | | Total calcium = 1,50–,999 mg/d | nd | nd | 207 | Nd | | | 1.06 | 0.91–1.23
| | | Total calcium = ≥ 2,000 mg/d | nd | nd | 85 | nd | | | 1.28 | 1.02–1.60
| | Fatal prostate cancer | Total calcium <500 mg/d | nd | nd | 21 | Nd | adjusted | RR | 1.05 | 0.65–1.69 | | 0.01
| | | Total calcium = 50–49 mg/d | nd | nd | 94 | Nd | | | 1 | Reference
| | | Total calcium = 75–99 mg/d | nd | nd | 81 | Nd | | | 0.95 | 0.70–1.28
| | | Total calcium = 1,00–,499 mg/d | nd | nd | 76 | Nd | | | 1.04 | 0.77–1.42
| | | Total calcium = 1,50–,999 mg/d | nd | nd | 26 | Nd | | | 1.56 | 1.00–2.43
| | | Total calcium = ≥ 2,000 mg/d | nd | nd | 14 | Nd | | | 2.02 | 1.14–3.58

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
16492906 | Giovannucci 2006 | a) Eligibility criteria clear? (y/n) | y | a) Exposure assessor blinded to outcome info? (y/n) | y | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | Y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
16492906 | Giovannucci 2006 | b) Sampling of population random or consecutive? (y/n) | NA | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | N | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | NA | b) Analysis was planned when cohort was formed? (y/n) | N
16492906 | Giovannucci 2006 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Y | | | | | b) Justification of final adjusted model selection? (y/n) | n | c) Do the authors specify a primary outcome? (y/n) | n | c) Justification of sample size (includes sample size calculations)? (y/n) | n
OVERALL Grade (A/B/C): | | | | | | | A
Explanation for Overall Quality Grade (if not Grade A):

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Giovannucci 2008

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
18541825 | Giovannucci 2008 | Case-cohort study | US male health care professionals Provided blood sample Age 40–75 in 1986 | History of CVD pre-1994. Participant reported MI not confirmed by medical records. Non-CVD death | Blood sample drawn 1/1993–12/1995 CVD assessed through 1/31/2004 | Health Professionals Follow-up Study (HPFS) | Gov’t (NIH) | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake...etc.)
18541825 | Giovannucci 2008 | Case- cohort study | US-wide (~25–45) | 18225 | 1354: 454 cases 900 controls | 63.8 (8.6) (implied at time of blood draw) | 40–75 | 100% | White 94% AA 0% Asian 0.7% Other 5% | BMI Cases: 26.1 (3.3) Controls 25.6 (3.4) P=.01 difference | No CVD (baseline) Current smoker 9.3% FHx MI<60 16% DM 9.3% HTN 37% | Total fat intake 31% of Kcal Saturated fat 10% Marine O3 0.12% Multivitamin use 47% (of cases)

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Background exposure data
18541825 | Giovannucci 2008 | 25(OH)D | | | | RIA (Hollis 1993) | Yes CV=11.5% | Unclear (but frozen) | Mean (SD) Cases 23.0 (7.6) Controls 24.5 (8.3) % in 4 categories, controls only: ≤15 ng/mL 9.7% 15.1–22.5 34% 22.6–29.9 33% ≥30 23%
| | Dietary calcium intake

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
18541825 | Giovannucci 2008 | Primary (for post hoc analysis) | Nonfatal MI or fatal CHD | By questionnaire: “professionally diagnosed” Medical record review (confirmed) by study MDs: MI – WHO criteria Deaths identified from state and national records, next of kin, or postal system. Fatal CHD: confirmed by hospital records, autopsy, or cause of death on death certificate if evidence of previous CHD was available. Nonfatal MI 352 participants; Fatal CHD 102 participants.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
18541825 | Giovannucci 2008 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes | Marine O3 intake (adjusted)
18541825 | Giovannucci 2008 | Demographics (e.g., age, gender, race, education)? | Yes | Age (matched)
18541825 | Giovannucci 2008 | | | Gender (all male)
18541825 | Giovannucci 2008 | | | Ethnicity, white vs other (adjusted)
18541825 | Giovannucci 2008 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI (adjusted)
18541825 | Giovannucci 2008 | Medical conditions | Yes | DM (adjusted)
18541825 | Giovannucci 2008 | | | HTN (adjusted)
18541825 | Giovannucci 2008 | Medication
18541825 | Giovannucci 2008 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | Yes | Physical activity (adjusted) US region (northeast, mid-Atlantic, Midwest, south) (adjusted) Month and year of blood draw (matched)
18541825 | Giovannucci 2008 | Smoking and other life styles variables | Yes | Smoking status (matched)
18541825 | Giovannucci 2008 | | | Alcohol intake (adjusted)
18541825 | Giovannucci 2008 | Other | Yes | Family history of MI<60 y (adjusted)
18541825 | Giovannucci 2008 | | | Baseline LDL-c (adjusted)
18541825 | Giovannucci 2008 | | | Baseline HDL-c (adjusted)
18541825 | Giovannucci 2008 | | | Triglycerides (adjusted)

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | F/up | N Event | N Total | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups *** | P for trend ****
18541825 | Giovannucci 2008 | Nonfatal MI or fatal CHD | 25(OH)D Level 1 | ≤15.0 ng/mL | 10 y | 63 | 150 | Adjusted | RR | 2.09 | 1.24, 3.54 | <.05
| | | Level 2 | 15.1–22.5 | | 156 | 463 | | | 1.43 | 0.96, 2.13 | NS
| | | Level 3 | 22.6–29.9 | | 165 | 464 | | | 1.60 | 1.10, 2.32 | <.05
| | | Level 4 | ≥30.0 | | 70 | 277 | | | 1.00 | -- | -- | .02
18541825 | Giovannucci 2008 | Nonfatal MI or fatal CHD | All | All | 10 y | 454 | 1354 | Adjusted | OR (per 1 ng/mL) | 0.98 | 0.96, 0.998 | | .05
18541825 | Giovannucci 2008 | Nonfatal MI or fatal CHD | All | All | 10 y | 454 | 1354 | Adjusted | Risk reduction per 1 ng/mL | | −2.1% | −0.2%, −4.0% | <.05
18541825 | Giovannucci 2008 | Nonfatal MI or fatal CHD | 25(OH)D Level 1 | ≤15.0 ng/mL | 10 y | nd | nd | Adjusted | RR No cholesterol lowering drugs at baseline | 2.30 | 1.33, 3.97 | <.05
| | | Level 4 | ≥30.0 ng/mL | | | | | | 1.0 | -- | --

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

MEAN DATA

THIS SHOULD ONLY APPLY TO CASE-COHORT STUDIES THAT COMPARE BASELINE VIT D/CA LEVELS BETWEEN CASES (WITH DISEASE) AND CONTROLS (WITHOUT DISEASE)

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Mean 25(OH)D Level | Vit D level SD | P between groups
18541825 | Giovannucci 2008 | Cases: | 10 y | Crude | 454 | 23.0 | 7.6 | .002
| | Control: | | | 900 | 24.5 | 8.3

Duplicate one table per outcome

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
18541825 | Giovannucci 2008 | The most adjusted model was chosen. Similar results (somewhat “stronger”) if only accounted for matching variables. Very similar results if omitted lipid-adjustment.

No statistical evidence of interaction by age (range approximately 48–83).

Interaction data also reported for HTN, BMI, aspirin use, physical activity, alcohol use, LDL-c, Tg, HDL-c.

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
18541825 | Giovannucci 2008 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | Y | a) Method reported? (y/n) | NA | a) One of the prespecified methods *** was used? (y/n) | Y | a) Level of the exposure in comparative categories (eg quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
18541825 | Giovannucci 2008 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | Y | b) Food composition database or suppl composition reported? (y/n) | NA | Time from sample collection to sample analysis reported? (y/n) | Y | a) Level of the exposure in comparative categories (eg quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | NA | b) Analysis was planned when cohort was formed? (y/n) | N
18541825 | Giovannucci 2008 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | NA | | | | | b) Justification of final adjusted model selection? (y/n) | +/− | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | A
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Appropriate matching, adjustment, and statistical analysis. No clear flaws.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Grau 2003

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusions | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
14652238 | Grau 2003 | Post hoc analysis of an existing RCT | Subjects had at least one histologically confirmed large-bowel adenoma removed within 3 months before recruitment, with the entire large-bowel mucosa visualized endoscopically and judged to be free of remaining polyps. | nd | 1988 | Calcium Polyp Prevention Study | nd | JHL/TTe

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
14652238 | Grau 2003 | Post hoc analysis of an existing RCT | Six clinical centers: the Cleveland Clinic Foundation, Dartmouth- Hitchcock Medical Center, the University of Southern California —Southern California Permanente Medical group, the University of Iowa, the University of Minnesota, and the University of North Carolina | 930 | 803 | 60.9 (nd) | nd | 72.5% | White - 84.4% Black - 8.3% Hispanic - 7.2% | nd | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
14652238 | Grau 2003 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | Radioimmunoassay kit from Nicholas Institute Diagnostics (Capistrano, CA) | Y, inter-batch Pearson correlation coefficient 25(OH)VitD=.95 1,25(OH)2VitD=.58 | 11–15y (1988–1992 to ~2003) | nd | nd
14652238 | Grau 2003 | Dietary calcium intake | SFFQ | nd | nd | nd | nd | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
14652238 | Grau 2003 | Ca | Ca supplementation (no brand name) | 3g of calcium carbonate or 1200mg of elemental calcium | 4 y | nd
| | placebo | nd | N/A | 4 y | nd
Co-intervention(s) * :

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
14652238 | Grau 2003 | 1° | Recurrence of colorectal adenomas | nd
14652238 | Grau 2003 | 2° | Occurrence of “advanced” colorectal adenomas (i.e., advanced lesions only) | Defined by the study pathologists as advanced lesions: tubulovillous adenomas (25–74% villous component), villous adenomas (75% or more villous), this containing advanced dysplasia or invasive cancer, or those larger than 1cm in diameter (as assessed by the endoscopist)

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
14652238 | Grau 2003 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
14652238 | Grau 2003 | Demographics (e.g., age, gender, race, education)? | Yes - age, gender
14652238 | Grau 2003 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No
14652238 | Grau 2003 | Medical conditions
14652238 | Grau 2003 | Medication
14652238 | Grau 2003 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | Yes - month of blood draw
14652238 | Grau 2003 | Smoking and other life styles variables | Yes - alcohol intake, smoking status
14652238 | Grau 2003 | Other | Center, VDR genotypes

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow- up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Mean Follow- up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | Result | 95% CI | P btw
14652238 | Grau 2003 | Recurrent adenoma [25(OH)D≤29.1ng/mL] | Placebo | 4 y | 95 | 203 | RR | | | | 1.05 | 0.85–1.29 | Interaction P=0.012
14652238 | Grau 2003 | Recurrent adenoma [25(OH)D≤29.1ng/mL] | Calcium | | 99 | 200 | RR | | | | 1.05 | 0.85–1.29 | Interaction P=0.012
14652238 | Grau 2003 | Recurrent adenoma [25(OH)D>29.1ng/mL] | Placebo | 4 y | 107 | 200 | RR | | | | 0.71 | 0.57–0.89 | Interaction P=0.012
14652238 | Grau 2003 | Recurrent adenoma [25(OH)D>29.1ng/mL] | Calcium | | 75 | 195 | RR | | | | 0.71 | 0.57–0.89 | Interaction P=0.012
14652238 | Grau 2003 | Recurrent “advanced” adenoma[25(OH)D≤29.1ng/mL] | Placebo | 4 y | 30 | 203 | RR | | | | 1.02 | 0.63–1.64 | Interaction P=0.106
14652238 | Grau 2003 | Recurrent “advanced” adenoma[25(OH)D≤29.1ng/mL] | Calcium | | 28 | 200 | RR | | | | 1.02 | 0.63–1.64 | Interaction P=0.106
14652238 | Grau 2003 | Recurrent “advanced” adenoma [25(OH)D>29.1ng/mL] | Placebo | 4 y | 39 | 200 | RR | | | | 0.58 | 0.36–0.93 | Interaction P=0.106
14652238 | Grau 2003 | Recurrent “advanced” adenoma [25(OH)D>29.1ng/mL] | Calcium | | 23 | 195 | RR | | | | 0.58 | 0.36–0.93 | Interaction P=0.106

* Example: OR Ca/placebo

Similar findings were observed when V-D levels were considered in tertiles or quartiles.

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases * | Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
14652238 | Grau 2003 | Recurrent adenoma vs. a unit (12 ng/mL) change in 25(OH)D | Overall | | | | | adj | RR | 0.99 | 0.91–1.07 | Interaction(calcium vs. placebo) P=0.006
| | | Calcium | | | | | adj | RR | 0.88 | 0.77–0.99 | Interaction(calcium vs. placebo) P=0.006
| | | placebo | | | | | adj | RR | 1.09 | 0.97–1.22 | Interaction(calcium vs. placebo) P=0.006
14652238 | Grau 2003 | Recurrent “advanced” adenoma vs. a unit (12 ng/mL) change in 25(OH)D | Overall | | | | | adj | RR | 0.95 | 0.79–1.15 | Interaction (calcium vs. placebo) P=0.48
| | | Calcium | | | | | adj | RR | 0.78 | 0.58–1.05 | Interaction (calcium vs. placebo) P=0.48
| | | placebo | | | | | adj | RR | 1.10 | 0.86–1.40 | Interaction (calcium vs. placebo) P=0.48

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
14652238 | Grau 2003 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | nd | a) Method reported? (y/n) | NA | a) One of the prespecified methods *** was used? (y/n) | Y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
14652238 | Grau 2003 | b) Sampling of population random or consecutive? (y/n) | N | b) Outcome assessor blinded to exposure measurement? (y/n) | Y | b) Food composition database or suppl composition reported? (y/n) | NA | Time from sample collection to sample analysis reported? (y/n) | N | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
14652238 | Grau 2003 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | NA | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Post-hoc “subgroup” analyses of a RCT. Consecutiveness not fully preserved. No controlling for family history of colorectal cancer

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Grau 2007

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17227996 | Grau 2007 | RCT | Subjects had at least one histologically confirmed adenoma within 3 months before enrollment, with the large bowel mucosa entirely examined and judged free of remaining polyps. | Subjects diet during Calcium trial, died after Calcium Trial and before Calcium follow-up, refused to participate, or unable to be contacted | 1988–1992 | Calcium Polyp Prevention Study | National Institute of Health | JHL

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc.) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
17227996 | Grau 2007 | RCT | US The Cleveland Clinic Foundation (41.51° N), Dartmouth Hitchcock Medical Center (43.71° N), The University of South California- Southern California Kaiser Permanente Medical Group (34.02° N), the University of Iowa (41.39° N), the University of Minnesota (44.98° N), and the University of North Carolina (35.94° N) | 930 | 822 | 60.6 (no sd) | nd | Male 71.7% Female 28.3% | nd | nd | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
17227996 | Grau 2007 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | nd | nd | nd | nd
17227996 | Grau 2007 | Dietary calcium intake | Semiquantitative food frequency questionnaire | nd | nd | nd | nd | | nd | 876 mg

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
17227996 | Grau 2007 | Ca | Ca supplementation | 1200mg of elemental calcium (3g of calcium carbonate) | 4y | 1 time/day
17227996 | Grau 2007 | placebo | nd
Co-intervention(s) * : | | | None
Compliance/Adherence: | | | 50% (no information on measurement)

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17227996 | Grau 2007 | Primary | All adenomas | For each colonoscopy a participant reported, copies of the endoscopy report and relevant pathology reports were obtained. Slides of each lesion removed from the bowel were sent to a study pathologist for uniform review regarding diagnosis and, for neo-plastic lesions, the degree of dysplasia. If the local and study pathologists disagreed, we accepted the study pathologist’s diagnosis.
17227996 | Grau 2007 | nd | Advance adenomas | Advanced lesions were defined as adenomas with at least 25% villous component, those containing advanced dysplasia or invasive cancer, or those with an estimated diameter of at least 1 cm (as assessed by the endoscopist)

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17227996 | Grau 2007 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | | For analysis of subjects who did not take calcium supplements before the first colonoscopy in the follow-up period, RR were adjusted fir age, sex, center, follow-up time and number of colonoscopies from the end of the active trial up to the last colonoscopy in the follow-up period under consideration.
17227996 | Grau 2007 | Demographics (e.g., age, gender, race, education)? | Yes * - Age, gender
17227996 | Grau 2007 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no *
17227996 | Grau 2007 | Medical conditions
17227996 | Grau 2007 | Medication
17227996 | Grau 2007 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
17227996 | Grau 2007 | Smoking and other life styles | no *
17227996 | Grau 2007 | variables (e.g., physical activity, occupation, alcohol consumption)
17227996 | Grau 2007 | Other | Center, follow-up time, number of colonoscopies from the end of the active trial up to the last colonoscopy in the follow-up period under consideration, and calcium supplement use before the first colonoscopy in the follow-up period under consideration.

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | Result | 95% CI | P btw
17227996 | Grau 2007 | All adenomas | Calcium group | 5 years | 51 | 162 | RR | | | | 0.63 | 0.46–0.87 | nd
17227996 | Grau 2007 | All adenomas | Placebo group | 5 years | 80 | 185 | RR | | | | 0.63 | 0.46–0.87 | nd
17227996 | Grau 2007 | All adenomas | Calcium group | 5–10 years | 82 | 208 | RR | | | | 1.09 | 0.85–1.39 | nd
17227996 | Grau 2007 | All adenomas | Placebo group | 5–10 years | 82 | 216 | RR | | | | 1.09 | 0.85–1.39 | nd
17227996 | Grau 2007 | Advanced adenomas | Calcium group | 5 years | 21 | 162 | RR | | | | 0.85 | 0.43–1.69 | nd
17227996 | Grau 2007 | Advanced adenomas | Placebo group | 5 years | 23 | 185 | RR | | | | 0.85 | 0.43–1.69 | nd
17227996 | Grau 2007 | Advanced adenomas | Calcium group | 5–10 years | 26 | 208 | RR | | | | 1.10 | 0.65–1.88 | nd
17227996 | Grau 2007 | Advanced adenomas | Placebo group | 5–10 years | 26 | 216 | RR | | | | 1.10 | 0.65–1.88 | nd

* Example: OR Ca/placebo

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

Subjects who did not take calcium supplements before the first colonoscopy in the follow-up period

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | Result | 95% CI | P btw
17227996 | Grau 2007 | All adenomas | Calcium group | 5 years | 28 | 102 | RR | | | | 0.59 | 0.40–0.90 | nd
17227996 | Grau 2007 | All adenomas | Placebo group | 5 years | 48 | 114 | RR | | | | 0.59 | 0.40–0.90 | nd
17227996 | Grau 2007 | All adenomas | Calcium group | 5–10 years | 53 | 121 | RR | | | | 1.05 | 0.77–1.43 | nd
17227996 | Grau 2007 | All adenomas | Placebo group | 5–10 years | 50 | 123 | RR | | | | 1.05 | 0.77–1.43 | nd
17227996 | Grau 2007 | Advanced Adenomas | Calcium group | 5 years | 10 | 102 | RR | | | | 0.62 | 0.29–1.33 | nd
17227996 | Grau 2007 | Advanced Adenomas | Placebo group | 5 years | 14 | 114 | RR | | | | 0.62 | 0.29–1.33 | nd
17227996 | Grau 2007 | Advanced Adenomas | Calcium group | 5–10 years | 18 | 121 | RR | | | | 1.18 | 0.57–2.43 | nd
17227996 | Grau 2007 | Advanced Adenomas | Placebo group | 5–10 years | 15 | 123 | RR | | | | 1.18 | 0.57–2.43 | nd

* Example: OR Ca/placebo

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
17227996 | Grau 2007 | RCT-Parallel | nd | nd | NA | n | y | y | y | y | y | B
Adverse Event(s): **
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Only 597 subjects in the Calcium Follow-up Study (74%) underwent at least one colonoscopy, no uniform interval between the end of the active trial and the first post-treatment colonoscopy. No details about the frequency of use and dose of elemental calcium in the supplements taken during the observational post- intervention phase

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT– Parallel, RCT– Cross-over, RCT– Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Harris 1999

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
10511329 | Harris 1999 | RCT | men 20–35 y or 60–75 y | travel to southern areas in last month; vit D supplement in last 6 mo; outdoor occupation; calcium >600 mg/d; calcium supplement in last 6 mo; meds that affect vit D metabolism; >3 alcohol drinks/d; kidney stone last 5 y; liver, kidney, gastrointestinal diseases | nd | - | USDA | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc.) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
10511329 | Harris 1999 | RCT | Boston, MA | 20 | 18 | Young: 26 Old: 69 | nd | 100 | nd | BMI Young: 26.6 Old: 31 | nd | vit D intake Young: 51 IU/d Old: 90 IU/d

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data ...etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
10511329 | Harris 1999 | 25(OH)D | | | | HPLC | inter- and intraassay CV: 10%, 8% (external validity) | 3 wks | February | vit D intake Young: 51 IU/d Old: 90 IU/d
| | Dietary calcium intake

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
10511329 | Harris 1999 | vit D2 placebo | Drisdol (Sanofi Winthrop, NY) | 1800 IU/d | 3 wk | qAM
Co-intervention(s) * :
Compliance/Adherence: | | | nd

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
10511329 | Harris 1999 | secondary | 25(OH)D total | sum of D2 and D3
| | primary | 25(OH)D2
| | primary | 25(OH)D3

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
10511329 | Harris 1999 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake Demographics (e.g., age, gender, race, education)? | Yes * | age
10511329 | Harris 1999 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes * | BMI
10511329 | Harris 1999 | Medical conditions
10511329 | Harris 1999 | Medication
10511329 | Harris 1999 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | Yes | blood drawn in February in Boston
10511329 | Harris 1999 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes/no *
10511329 | Harris 1999 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline SD * | Delta ** | Delta SD * | Net difference | Net difference CI/SE/SD * | P between
10511329 | Harris 1999 | change in 25(OH)D2 in young | nmol/L | vit D2 supplment | 3 wk | 6 | 0 | 0 | 37 | 9.4 | | | nd
10511329 | Harris 1999 | change in 25(OH)D2 in young | nmol/L | placebo | | 3 | 7.5 | 13 | −7.5 | 13
| | change in 25(OH)D2 in old | nmol/L | vit D2 supplment | 3 wk | 5 | 0 | 0 | 19.5 | 12.8 | | | nd
| | change in 25(OH)D2 in old | nmol/L | placebo | | 4 | 5.0 | 10.0 | 0.0 | 0.0
| | change in 25(OH)D3 in young | nmol/L | vit D2 supplment | 3 wk | 6 | 32.4 | 10.7 | −6.7 | 6.8 | | | nd
| | change in 25(OH)D3 in young | nmol/L | placebo | | 3 | 34.9 | 0.0 | −1.7 | 6.3
| | change in 25(OH)D3 in old | nmol/L | vit D2 supplment | 3 wk | 5 | 39.9 | 9.3 | −12.0 | 5.7 | | | nd
| | change in 25(OH)D3 in old | nmol/L | placebo | | 4 | 34.9 | 6.1 | −3.7 | 6.3
| | change in total 25(OH)D in young | nmol/L | vit D2 supplment | 3 wk | 6 | 32.4 | 10.7 | 30.4 | 9.5 | | | nd
| | change in total 25(OH)D in young | nmol/L | placebo | | 3 | 42.4 | 13 | −9.2 | 15
| | change in total 25(OH)D in old | nmol/L | vit D2 supplment | 3 wk | 5 | 39.9 | 9.3 | 7.5 | 13 | | | nd
| | change in total 25(OH)D in old | nmol/L | placebo | | 4 | 39.9 | 6.1 | −3.7 | 6.3

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
10511329 | Harris 1999 | | ANOVA of the 3-wk change in 25(OH)D2 showed a significant interaction between age and supplementation group (P=0.02)

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
10511329 | Harris 1999 | RCT | nd | nd | NA | y | n | n | n | y | y | C
Adverse Event(s): ** | | | | | | None
Explanation for Overall Quality Grade (if not Grade A): | | | | | | small sample size; compliance not reported; did not report all relevant statistical analyses

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT– Parallel, RCT– Cross-over, RCT– Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse

## Hartman 2005

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
15671222 | Hartman 2005 | Cohort study Participants are included in an RCT | Subjects ≥35 yr with 1 or more histologically confirmed colorectal adenomas identified by complete colonoscopy | Subjects must not have had resected adenomatous polyps previously, nor could have been diagnosed with cololectal cancer, inflammatory bowel disease, or polyposis syndrome, ≤150% of their recommended weight and could not be currently using lipid-lowering medications. | 1991–1994 | The Polyp Prevention Trial | nd | JHL

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
15671222 | Hartman 2005 | Cohort study Participants are included in an RCT | US 38° N, 8 clinical centers | 2079 | 1905 | 61.1(9.9) | nd | 64 | Caucasian 90% | nd | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data ...etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
15671222 | Hartman 2005 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | nd | nd | nd | VitD 4.4±2.4 μg/d
15671222 | Hartman 2005 | Dietary calcium intake | FFQ | USDA | Y (4 day food records from a subset) | nd | nd | | nd | 981± 435 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
15671222 | Hartman 2005 | nd | Recurrent adenomas | Ascertained by complete colonoscopy at baseline and after 1 and 4y
15671222 | Hartman 2005 | nd | Advanced adenomas | Subjects had maximal diameter ≥1 cm or had at least 25% villous elements or displayed evidence of high-grade dysplasia.

UI | Author Year | Comments
15671222 | Hartman 2005 | This original study (The Polyp Prevention Trial) was a multicenter randomized clinical trial designed to determine the effects of a high-fiber, high-fruit and vegetable, low fat diet on the recurrent of adenomatous polyps in the large bowel. For this study, the association of calcium with risk of colorectal adenomas was examined.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
15671222 | Hartman 2005 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Energy intake
15671222 | Hartman 2005 | Demographics (e.g., age, gender, race, education)? | Yes/no * - age, gender
15671222 | Hartman 2005 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes/no *
15671222 | Hartman 2005 | Medical conditions
15671222 | Hartman 2005 | Medication | Use of nonsteroidal anti-inflammatory drugs
15671222 | Hartman 2005 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
15671222 | Hartman 2005 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes/no *
15671222 | Hartman 2005 | Other | Intervention assignment, gender * intervention group

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non- cases/Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
15671222 | Hartman 2005 | Recurrent adenomas | Ca quintile 1 | | < 666 mg/d | 156 | nd | Adjusted | OR | 1.0 | | | 0.20
| | | Ca quintile 2 | | 666– 814 | 163 | nd | Adjusted | OR | 1.12 | 0.83– 1.51
| | | Ca quintile 3 | | 815– 969 | 154 | nd | Adjusted | OR | 1.02 | 0.76– 1.38
| | | Ca quintile 4 | | 970– 1226 | 150 | nd | Adjusted | OR | 1.00 | 0.74– 1.36
| | | Ca quintile 5 | | >1226 | 131 | nd | Adjusted | OR | 0.86 | 0.62– 1.18
15671222 | Hartman 2005 | Advanced adenomas | Ca quintile 1 | | < 666 mg/d | 23 | nd | Adjusted | OR | 1.0 | | | 0.98
| | | Ca quintile 2 | | 666– 814 | 26 | nd | Adjusted | OR | 1.19 | 0.66– 2.16
| | | Ca quintile 3 | | 815– 969 | 22 | nd | Adjusted | OR | 1.00 | 0.54– 1.85
| | | Ca quintile 4 | | 970– 1226 | 23 | nd | Adjusted | OR | 1.56 | 0.88– 2.77
| | | Ca quintile 5 | | >1226 | 21 | nd | Adjusted | OR | 0.93 | 0.49– 1.79
15671222 | Hartman 2005 | Multiple recurrent adenomas | Ca quintile 1 | | < 666 mg/d | 58 | nd | Adjusted | OR | 1.0 | | | 0.36
| | | Ca quintile 2 | | 666– 814 | 73 | nd | Adjusted | OR | 1.33 | 0.90– 1.96
| | | Ca quintile 3 | | 815– 969 | 71 | nd | Adjusted | OR | 1.29 | 0.87– 1.92
| | | Ca quintile 4 | | 970– 1226 | 69 | nd | Adjusted | OR | 1.30 | 0.87– 1.93
| | | Ca quintile 5 | | >1226 | 47 | nd | Adjusted | OR | 0.88 | 0.56– 1.36

Duplicate one row per exposure category or intervention group

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
15671222 | Hartman 2005 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | N | Y a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | N | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
15671222 | Hartman 2005 | b) Sampling of population random or consecutive? (y/n) | y | b) Outcome assessor blinded to exposure measurement? (y/n) | n | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | N | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up<20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
15671222 | Hartman 2005 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | N | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Power calculation not performed; study not initially designed for assessing the relation between calcium intake and adenomas; blinding not reported

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Harvey-Berino 2005

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
16286519 | Harvey-Berino 2005 | RCT | Age 18 to 60 years, BMI between 25 and 34.9, current calcium consumption ≤500 mg/d, current dairy product consumption < 1 serving/d, no medical problems that would contraindicate calorie restriction, non-smokers, agreement to follow study diet as prescribed | History of major medical or psychiatric problems including metabolic disease (i.e. hepatic, endocrine, or renal disease), diabetes requiring oral agents or insulin, lactose intolerance, planned a pregnancy within next 12 months, unable to participate in exercise program, unwilling to stop taking dietary supplements, taking medications that would influence metabolism or weight change. | Nd | Nd | National Dairy Council, Northeast Dairy Foods Research Center, University of Vermont, Cabot Cheese | KP

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
16286519 | Harvey-Berino 2005 | RCT | Vermont, USA 44°N | 54 | 44 | 45.2(6.7) | 18–60 | 7% | Nd | BMI = 30(2.5), weight = 81(9), Body fat % = 44(4.8)% | Nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
16286519 | Harvey-Berino 2005 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | NA | NA | NA | NA | NA
| | Dietary calcium intake | 7-day food record | Other (Food Processor, version 7.9, ESHA, Salem, OR) | N | NA | NA | | NA | NA

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
16286519 | Harvey-Berino 2005 | Dairy (high Ca) | 3–4 dairy servings/d (milk, yogurt, cheese) | Goal of 1200 to 1400 g/d Ca | 12 months | Nd
| | Control (low Ca) | One dairy serving/d | Goal of 400–500 mg/d Ca | 12 months | nd
Co-intervention(s) * : | | | Calorie restriction in both groups with behavioral weight loss program, aiming for 500 kcal/d restriction from baseline levels
Compliance/Adherence: | | | 7 dropped out from not being able to follow menus

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
16286519 | Harvey-Berino 2005 | Primary | Body weight | Change in bodyweight in kg

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
16286519 | Harvey-Berino 2005 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
16286519 | Harvey-Berino 2005 | Demographics (e.g., age, gender, race, education)? | No
16286519 | Harvey-Berino 2005 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no
16286519 | Harvey-Berino 2005 | Medical conditions
16286519 | Harvey-Berino 2005 | Medication
16286519 | Harvey-Berino 2005 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
16286519 | Harvey-Berino 2005 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no
16286519 | Harvey-Berino 2005 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline CI/SE/SD * | Final or Delta ** | Final or Delta CI/SE/SD * | Net difference | Net difference CI/SE/SD * | P between
16286519 | Harvey-Berino 2005 | Body weight | Kg | High dairy | 12 mo. | 23 | 82.7 | SD = 10.0 | Delta =−10.8 | SD =5.9 | −1.2 | Nd | 0.56
16286519 | Harvey-Berino 2005 | Body weight | Kg | Low dairy | 12 mo. | 21 | 80.9 | SD = 8.7 | Delta =−9.6 | SD =6.5

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−” sign: e.g. +2.8 or −2.8

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
16286519 | Harvey-Berino 2005 | RCT-parallel | nd | Nd | Nd | Y | Nd | N | Y | N | Y | B
Adverse Event(s): ** | | | | | | Nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Not much explanation of methodology with respect to randomization, blinding

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Hatton 2003

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
14553957 | Hatton 2003 | RCT | Completed CPEP trial protocol; in Oregon Delivered an infant without serious health problems Previously nulliparous Read English | CKD, calciuria, hematuria, urolithiasis, frequent Ca supplements or antacids | ≤ 1996 | Calcium for Prevention of Preeclampsia Trial (CPEP) [Oregon center only] | GSK NIH | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
14553957 | Hatton 2003 | RCT | Portland, OR 45.5° | 497 | 62 | nd | nd | 0 | nd | nd | Healthy | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
14553957 | Hatton 2003 | Dietary calcium intake | none | NA | NA | none | NA | | nd | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
14553957 | Hatton 2003 | Ca supplement | Ca carbonate | 2 g | ~20–30 weeks (during pregnancy until delivery) | 2×500 mg capsules 2x/day with meals
| | Placebo
Co-intervention(s) * : | | | All received prenatal vitamin (Ca 50 mg, Fe 30 mg, vit D _ 2 _ 400 IU, other vitamins)
Compliance/Adherence: | | | nd (but all had to meet a compliance test prior to randomization)

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
14553957 | Hatton 2003 | 2° | BP (post-partum)

UI | Author Year | Comments
14553957 | Hatton 2003 | RCT was conducted during pregnancy. The calcium was discontinued upon delivery. The researchers then contacted women again and measured BP in children (primary focus) and mothers.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
14553957 | Hatton 2003 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
14553957 | Hatton 2003 | Demographics (e.g., age, gender, race, education)? | No
14553957 | Hatton 2003 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No
14553957 | Hatton 2003 | Medical conditions
14553957 | Hatton 2003 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
14553957 | Hatton 2003 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | No
14553957 | Hatton 2003 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline CI/SE/SD * | Final | Final SD | Net difference | Net difference CI/SE/SD * | P between
14553957 | Hatton 2003 | SBP | mm Hg | Ca supplement (prenatal) | 2 y | 37 | nd | nd | 101.9 | 12.9 | | | NS
14553957 | Hatton 2003 | SBP | mm Hg | Placebo | | 25 | nd | nd | 104.1 | 9.6
| | DBP | mm Hg | Ca supplement (prenatal) | 2 y | 37 | nd | nd | 67.1 | 7.7 | | | NS
| | DBP | mm Hg | Placebo | | 25 | nd | nd | 67.8 | 8.2

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
14553957 | Hatton 2003 | RCT | nd | nd | NA | No | nd | No | Unclear | No | No | C
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Outcome of convenience in post hoc analysis of small subgroup. Incomplete data presented. No adjustment

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Heaney 2003

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
12499343 | Heaney 2003 | RCT | men in good general health, ≤1 serving milk qD; planning winter vacation to areas with significant solar radiation | vitamin supplement | nd | - | Health Future Foundation | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
12499343 | Heaney 03 | RCT | Omaha, NE 41.2ºN | 67 | 67 | 38.7 (11.2) | nd | 100 | nd | BMI 26.2 (2.4) | good general health | est. <5 μg/d intake of vit D

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
12499343 | Heaney 2003 | 25(OH)D3 | | | | Nichols method (Nichols Institute Diagnostics); similar to IDS | nd | nd | October to March, 2 successive years | est. <5 μg/d intake of vit D
| | Dietary calcium intake

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
12499343 | Heaney 2003 | zero dose | | zero dose | ~20 wk
| | 1000 IU | Douglas Laboratory, Pittsburgh | 25 μg (1000 IU) | ~20 wk | 1 tab
| | 5000 IU | Tishcon, NY | 125 μg (5000 IU) | ~20 wk | 1 tab
| | 10000 IU | Tishcon, NY | 250 μg (10,000 IU) | ~20 wk | 2 tabs
Co-intervention(s) * :
Compliance/Adherence: | | | nd

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
12499343 | Heaney 2003 | primary | slope | Δ25(OH)D/Δ vitD dose

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
12499343 | Heaney 2003 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
12499343 | Heaney 2003 | Demographics (e.g., age, gender, race, education)? | Yes * | age, sex
12499343 | Heaney 2003 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes * | body weight, % body fat
12499343 | Heaney 2003 | Medical conditions
12499343 | Heaney 2003 | Medication
12499343 | Heaney 2003 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | Yes | UV exposure, location
12499343 | Heaney 2003 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no *
12499343 | Heaney 2003 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
12499343 | Heaney 2003 | Regression on actual dose | Δ25(OH)D3 (nmol/L)= −0.038 + 0.700 vitD dose (μg/d)

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
12499343 | Heaney 2003 | RCT | nd | nd | NA | nd | nd | nd | y | y | n | C
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | unclear how many subjects in each group; not all relevant data reported

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Heikkinen 1997

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
9405029 | Heikkinen 1997 | RCT | 47–56 yo women, Last menstrual period within 6.24 months prior to study | Contraindications for HRT | >=1989 | Kuopio Osteoporosis Risk Factor and Prevention Study | Schering, Professional Organization | KP

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SEM) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
9405029 | Heikkinen 1997 | RCT | Kuopio Province, Eastern Finland (63 °N) | 464 | 320 | 52.9(0.29) | 47–56 | 0% | Nd | 26.4(0.47) | Nd | Nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
9405029 | Heikkinen 1997 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | NA | NA | NA | NA | NA
| | Dietary calcium intake | NA | NA | NA | NA | NA | | NA | NA

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
9405029 | Heikkinen 1997 | Vit D3 plus Ca | D-Calsor, Orion Corporation, Espoo, Finland | 300 IU Vit D3/day, 500 mg/day calcium lactate | 30 mo | Nd
| | Ca | D-Calsor, Orion Corporation, Espoo, Finland | 500 mg/day calcium lactate | 30 mo | nd
Co-intervention(s) * : | | | Hormone replacement therapy (a third group was HRT+ Vit D, and a fourth was HRT alone)
Compliance/Adherence: | | | nd

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
9405029 | Heikkinen 1997 | secondary | Body weight | Change in kg over 30 months

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
9405029 | Heikkinen 1997 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
9405029 | Heikkinen 1997 | Demographics (e.g., age, gender, race, education)? | No
9405029 | Heikkinen 1997 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No
9405029 | Heikkinen 1997 | Medical conditions
9405029 | Heikkinen 1997 | Medication
9405029 | Heikkinen 1997 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
9405029 | Heikkinen 1997 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | No
9405029 | Heikkinen 1997 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline CI/SE/SD * | Final or Delta ** | Final or Delta CI/SE/SD * | Net difference | Net difference CI/SE/SD * | P between
9405029 | Heikkinen 1997 | Body weight | kg | Vit D3 plus Ca | 30 | 83 | 71.5 | SD = 1.24 | Final = 72.8 | Final SD = 1.3 | 0.9 | Nd | Not significant
9405029 | Heikkinen 1997 | Body weight | kg | Ca | 30 | 95 | 67.6 | SD = 1.07 | Final = 69.8 | Final SD = 1.26

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−” sign: e.g. +2.8 or −2.8

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
9405029 | Heikkinen 1997 | RCT- parallel | Yes | ND | NA | No | Nd | Nd | Yes | No | No | C
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Baseline weights are not evenly distributed between intervention groups. High dropout rate. Unclear if 3 year or 30 month data. No discussion of washout, blinding, intention to treat

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Hollis 2004; Basile 2006

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
15585800; 17661558 | Hollis 2004;Basile 2006 | RCT | Lactating mothers, within 1 month after birth, were recruited for inclusion in the study if they planned to fully breastfeed for the next 3 months | Preexisting type 1 or 2 diabetes, HTN, parathyroid disease, and uncontrolled thyroid disease. | nd | nd | NIH, Medical University of South Carolina | MC

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake...etc.)
15585800 | Hollis 2006 | RCT | Nd | 64 | 18 | 2000 IU grp: 29 (6) 4000 IU grp: 30.8 (5.2) | nd | 0 | White: 72%; African American: 28% | Mothers: nd Mean birth weight=3448 g | Mothers: healthy Infants: GA 36–41 weeks | Nd
17661558 | Basile 2006 | RCT | nd | 64 | 25 | 2000 IU grp: 30.6 (4.6) 4000 IU grp: 29.6 (4.9) | nd | 0 | White: 64%; African American: 36% | Mothers: nd Mean birth weight=3460 g (ranged 2315–4165) | Mothers: healthy Infants: mean GA 38 weeks | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
15585800; 17661558 | Hollis 2004;Basile 2006 | 25(OH)D | | | | HPLC and radioimmunoassay | nd | nd | nd | Subjects were instructed to limit sun exposure (for mother and infant). See results for baseline 25(OH)D levels
| | Dietary calcium intake | nd | | | nd | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
15585800; 17661558 | Hollis 2004;Basile 2006 | Group 1: vitamin D2 + multivitamin | Nd | 1600 IU vitamin D2 + 400 IU vitamin D3 | 3 months | Nd
15585800; 17661558 | Hollis 2004;Basile 2006 | Group 2: vitamin D2 + multivitamin | nd | 3600 IU vitamin D2 + 400 IU vitamin D3 | 3 months | nd
Co-intervention(s) * : | | | nd
Compliance/Adherence: | | | Compliance with vitamin d supplement (%):
Compliance/Adherence: | | | Group 1: returned month 1 = 10.3%, month 2 =12.1%; month 3=10.2%
Compliance/Adherence: | | | Group 2: returned month 1 = 8.4%, month 2 =10.4%; month 3=7.6%

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
15585800; 17661558 | Hollis 2004;Basile 2006 | Primary | Maternal circulating total 25(OH)D | Maternal serum total vitamin D2, total vitamin D3, 25(OH)D2, and 25(OH)D3
| | primary | Infant circulating total 25(OH)D | Infant serum total vitamin D2, total vitamin D3, 25(OH)D2, and 25(OH)D3

UI | Author Year | Comments
15585800; 17661558 | Hollis 2004; Basile 2006 | Also have separate results for changes in 25(OH)D2 and 25(OH)D3

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
15585800; 17661558 | Hollis 2004; Basile 2006 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
15585800; 17661558 | Hollis 2004; Basile 2006 | Demographics (e.g., age, gender, race, education)? | no *
15585800; 17661558 | Hollis 2004; Basile 2006 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no *
15585800; 17661558 | Hollis 2004; Basile 2006 | Medical conditions
15585800; 17661558 | Hollis 2004; Basile 2006 | Medication
15585800; 17661558 | Hollis 2004; Basile 2006 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
15585800; 17661558 | Hollis 2004; Basile 2006 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no *
15585800; 17661558 | Hollis 2004; Basile 2006 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline SD * | Final ** | Final SD * | Net difference | Net difference CI/SE/SD * | P between
17661558 | Basile 2006 | Maternal circulating total 25(OH)D | mg/dL | 2000 IU/d | 3 | 12 | 22.4 | 8.8 | 33.9 | 6.5 | nd | nd | 0.03
17661558 | Basile 2006 | Maternal circulating total 25(OH)D | mg/dL | 4000 IU/d | 3 | 13 | 28.5 | 8.6 | 43.0 | 11.6
17661558 | Basile 2006 | infant circulating total 25(OH)D | mg/dL | 2000 IU/d | 3 | 12 | 7.8 | 1.1 | 27.8 | 3.9 | nd | nd | 0.01
17661558 | Basile 2006 | infant circulating total 25(OH)D | mg/dL | 4000 IU/d | 3 | 13 | 13.4 | 3.3 | 30.8 | 5.0
15585800 | Hollis 2006 | Maternal circulating total 25(OH)D | Ng/mL | 2000 IU/d | 3 | 9 | 27.6 | 3.3 | 36.1 | 2.3 | nd | Nd | nd
15585800 | Hollis 2006 | Maternal circulating total 25(OH)D | Ng/mL | 4000 IU/d | 3 | 9 | 32.9 | 2.4 | 44.5 | 3.9
15585800 | Hollis 2006 | infant circulating total 25(OH)D | Ng/mL | 2000 IU/d | 3 | 9 | 7.9 | 1.1 | 27.8 | 3.9 | nd | nd | nd
15585800 | Hollis 2006 | infant circulating total 25(OH)D | Ng/mL | 4000 IU/d | 3 | 9 | 13.4 | 3.3 | 30.8 | 5.0

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−” sign: e.g. +2.8 or −2.8

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
15585800; 17661558 | Hollis 2004; Basile 2006 | RCT - parallel | nd | nd | NA | no | nd | no | no | no | no | C
Adverse Event(s): ** | | | | | | No episodes of hypercalciuria or hypercalcemia
Explanation for Overall Quality Grade (if not Grade A): | | | | | | It is very likely Basile and Hollis are the same study but the number of mother-infant pairs were different. Basile 2004 claimed that Hollis is the pilot study but the number of enrolled mothers (N=64) were the same and only a small fraction of mothers were included in the analyses. Although reported as a RCT, the analyses were done to compare within group changes only. Poor reporting of interventions and compliance.

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Hsia 2007

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17309935 | Hsia 2007 | RCT-post hoc | -Participant of WHI hormone therapy and/or dietary modification trial-Women, 50–79 yrs of age | -Menopausal | 1995–2005 | Women’s Health Initiative fracture trial | NHLBI | MB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
17309935 | Hsia 2007 | RCT-post hoc | Various (40 clinical sites) | 36,282 | 36,282 | 62 (7) | 50–79 | 0% | 83% white 9% black 4% Hispanic | BMI = 29 ± 6 Waist circumference = 89 ± 14 cm | “generally healthy” postmenopausal women | See background exposure data

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
17309935 | Hsia 2007 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | nd | nd | nd
| | Dietary calcium intake | | | | | | | | At baseline, mean Ca intake (diet + supplements) was1148 ± 654 mg/d in the active tx group and 1154 ± 658 mg/d in the placebo group.

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
17309935 | Hsia 2007 | Vit D/Ca | 25-hydroxy vit D3/calcium carbonate | 400 IU/1000 mg | Mean = 7.0 ± 1.4 yrs | 200 IU/500 mg 2x daily
| | Placebo | nd | - | Mean = 7.0 ± 1.4 yrs | Twice daily
Co-intervention(s) * : | | | Concurrent Ca supplementation was permitted, as was vit D, up to 400 IU daily.
Compliance/Adherence: | | | 60% of study participants took at least 80% of their study medication through year 6.

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17309935 | Hsia 2007 | 2° | Weight | nd
| | 2° | SBP | nd
| | 2° | DBP | nd
| | 2° | MI | Algorithm that included symptoms, ECG findings, and cardiac enzymes
| | 2° | CHD death | Centrally adjudicated
| | 2° | CABG or PCI | Hospital record review
| | 2° | Angina | Required hospitalization w/confirmatory stress test or obstructive coronary disease by angiography
| | 2° | Hospitalized heart failure | Hospital record review
| | 2° | Stroke | Rapid onset of a persistent neurological deficit not due to trauma, tumor, infection, or other cause
| | 2° | TIA | nd
| | | | For all outcomes, centrally trained physician-adjudicators classified outcomes on the basis of medical record review.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17309935 | Hsia 2007 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Ca and vit D intake | Groups matched on total Ca intake and total vit D intake (supplements + diet)
17309935 | Hsia 2007 | Demographics (e.g., age, gender, race, education)? | Yes | Groups matched on age and race
17309935 | Hsia 2007 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | Groups matched on BMI
17309935 | Hsia 2007 | Medical conditions | DM, high cholesterol requiring pills, CVD, CHD | Groups matched on these medical conditions
17309935 | Hsia 2007 | Medication | statin use, aspirin use, NSAID use, use of postmenopausal hormone therapy | Groups matched on use of these medications
17309935 | Hsia 2007 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | No
17309935 | Hsia 2007 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | Groups matched on smoking
17309935 | Hsia 2007 | Other | | Baseline characteristics were balanced between groups except for HTN (P = 0.03)

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | Result | 95% CI | P btw
17309935 | Hsia 2007 | MI | Ca/D | 7 yr | 411 | 18176 | Hazard Ratio | 1.05 | 0.91, 1.20 | 0.52
17309935 | Hsia 2007 | MI | Placebo | | 390 | 18106 | Hazard Ratio | 1.05 | 0.91, 1.20 | 0.52
| | CHD death | Ca/D | 7 yr | 130 | 18176 | Hazard Ratio | 1.01 | 0.79, 1.29 | 0.92
| | CHD death | Placebo | | 128 | 18106 | Hazard Ratio | 1.01 | 0.79, 1.29 | 0.92
| | MI or CHD death | Ca/D | 7 yr | 499 | 18176 | Hazard Ratio | 1.04 | 0.92, 1.18 | 0.50
| | MI or CHD death | Placebo | | 475 | 18106 | Hazard Ratio | 1.04 | 0.92, 1.18 | 0.50
| | CABG or PCI | Ca/D | 7 yr | 674 | 18176 | Hazard Ratio | 1.09 | 0.98, 1.22 | 0.12
| | CABG or PCI | Placebo | | 607 | 18106 | Hazard Ratio | 1.09 | 0.98, 1.22 | 0.12
| | MI/CHD death/CABG/PCI | Ca/D | 7 yr | 920 | 18176 | Hazard Ratio | 1.08 | 0.99, 1.19 | 0.10
| | MI/CHD death/CABG/PCI | Placebo | | 841 | 18106 | Hazard Ratio | 1.08 | 0.99, 1.19 | 0.10
| | Angina | Ca/D | 7 yr | 404 | 18176 | Hazard Ratio | 1.08 | 0.94, 1.24 | 0.30
| | Angina | Placebo | | 377 | 18106 | Hazard Ratio | 1.08 | 0.94, 1.24 | 0.30
| | Hospitalized heart failure | Ca/D | 7 yr | 394 | 18176 | Hazard Ratio | 0.95 | 0.83, 1.10 | 0.50
| | Hospitalized heart failure | Placebo | | 407 | 18106 | Hazard Ratio | 0.95 | 0.83, 1.10 | 0.50
| | Stroke | Ca/D | 7 yr | 362 | 18176 | Hazard Ratio | 0.95 | 0.82, 1.10 | 0.51
| | Stroke | Placebo | | 377 | 18106 | Hazard Ratio | 0.95 | 0.82, 1.10 | 0.51
| | TIA | Ca/D | 7 yr | 213 | 18176 | Hazard Ratio | 1.16 | 0.95, 1.42 | 0.13
| | TIA | Placebo | | 182 | 18106 | Hazard Ratio | 1.16 | 0.95, 1.42 | 0.13
| | Stroke/TIA | Ca/D | 7 yr | 563 | 18176 | Hazard Ratio | 1.02 | 0.91, 1.15 | 0.75
| | Stroke/TIA | Placebo | | 547 | 18106 | Hazard Ratio | 1.02 | 0.91, 1.15 | 0.75

* Example: OR Ca/placebo

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline SD * | Delta ** | Delta SD * | Net difference | Net difference CI/SE/SD * | P between
17309935 | Hsia 2007 | Weight | | Ca/D | 2 yr | 18176 | BMI=29.1 | 5.9 | +1.4% | 10.5 | −0.3% | | 0.03
17309935 | Hsia 2007 | Weight | | placebo | | 18106 | BMI=29.0 | 5.9 | +1.7% | 12.0
| | SBP | | Ca/D | 2 yr | 18176 | 127 | 17 | +1.1% | 12.4 | +0.4% | | 0.01
| | SBP | | placebo | | 18106 | 128 | 17 | +0.7% | 12.4
| | DBP | | Ca/D | 2 yr | 18176 | 76 | 9 | −0.2% | 12.4 | +0.4% | | 0.007
| | DBP | | placebo | | 18106 | 76 | 9 | −0.6% | 12.4

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−” sign: e.g. +2.8 or −2.8

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Age | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Age | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | Result | 95% CI | P btw
17309935 | Hsia 2007 | CHD (MI or CHD death) | 50–59 | Ca/D | 7 yr | 84 | | Hazard Ratio | 0.94 | 0.70–1.27 | >.05
17309935 | Hsia 2007 | CHD (MI or CHD death) | 50–59 | placebo | | 87 | | Hazard Ratio | 0.94 | 0.70–1.27 | >.05
| | | 60–69 | Ca/D | 7 yr | 239 | | Hazard Ratio | 1.08 | 0.90–1.30 | >.05
| | | 60–69 | placebo | | 220 | | Hazard Ratio | 1.08 | 0.90–1.30 | >.05
| | | 70–79 | Ca/D | 7 yr | 176 | | Hazard Ratio | 1.05 | 0.85–1.30 | >.05
| | | 70–79 | placebo | | 168 | | Hazard Ratio | 1.05 | 0.85–1.30 | >.05

* Example: OR Ca/placebo

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Age | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Age | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | Result | 95% CI | P btw
17309935 | Hsia 2007 | Stroke | 50–59 | Ca/D | 7 yr | 51 | | Hazard Ratio | 0.90 | 0.62–1.32 | >.05
17309935 | Hsia 2007 | Stroke | 50–59 | placebo | | 56 | | Hazard Ratio | 0.90 | 0.62–1.32 | >.05
| | | 60–69 | Ca/D | 7 yr | 164 | | Hazard Ratio | 0.97 | 0.78–1.20 | >.05
| | | 60–69 | placebo | | 170 | | Hazard Ratio | 0.97 | 0.78–1.20 | >.05
| | | 70–79 | Ca/D | 7 yr | 147 | | Hazard Ratio | 0.96 | 0.76–1.20 | >.05
| | | 70–79 | placebo | | 151 | | Hazard Ratio | 0.96 | 0.76–1.20 | >.05

* Example: OR Ca/placebo

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Total Ca intake, mg | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Total Ca intake, mg | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | Result | 95% CI | P btw
17309935 | Hsia 2007 | CHD (MI or CHD death) | <800 | Ca/D | 7 yr | 210 | | Hazard Ratio | 1.12 | | >.05
17309935 | Hsia 2007 | CHD (MI or CHD death) | <800 | placebo | | 181 | | Hazard Ratio | 1.12 | | >.05
| | | 800 – <1200 | Ca/D | 7 yr | 128 | | Hazard Ratio | 1.01 | | >.05
| | | 800 – <1200 | placebo | | 125 | | Hazard Ratio | 1.01 | | >.05
| | | ≥1200 | Ca/D | 7 yr | 143 | | Hazard Ratio | 0.93 | | >.05
| | | ≥1200 | placebo | | 158 | | Hazard Ratio | 0.93 | | >.05

* Example: OR Ca/placebo

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Total Ca intake, mg | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Total Ca intake, mg | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | Result | 95% CI | P btw
17309935 | Hsia 2007 | Stroke | <800 | Ca/D | 7 yr | 139 | | Hazard Ratio | 1.07 | | >.05
17309935 | Hsia 2007 | Stroke | <800 | placebo | | 127 | | Hazard Ratio | 1.07 | | >.05
| | | 800 – <1200 | Ca/D | 7 yr | 92 | | Hazard Ratio | 1.04 | | >.05
| | | 800 – <1200 | placebo | | 87 | | Hazard Ratio | 1.04 | | >.05
| | | ≥1200 | Ca/D | 7 yr | 121 | | Hazard Ratio | 0.80 | | >.05
| | | ≥1200 | placebo | | 152 | | Hazard Ratio | 0.80 | | >.05

* Example: OR Ca/placebo

Subgroup Analyses Comments

UI | Author Year | Comments for Results
17309935 | Hsia 2007 | Other subgroups evaluated: BMI, waist circumference, diabetes, smoking, HTN, high cholesterol requiring medication, CHD risk factors, CHD at baseline, CVD at baseline, statin use at baseline, aspirin use at baseline, dietary Ca intake, total vit D intake, EtOH use, HRT arm, dietary modification arm. CHD risk with active vit D/Ca was inversely related to BMI. Stroke risk with active vit D/Ca was lower among women with high cholesterol and those taking statins at baseline. Stroke risk was with active vit D/Ca was also inversely related to the number of CHD risk factors. All other demographic/clinical characteristics were not statistically significant.

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
17309935 | Hsia 2007 | RCT-post hoc | Nd # | Nd # | NA | Y | Y | nd | Y | Y | Y | B
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | It was the consensus among the Tufts EPC that overall, the methodological quality of the trial was B, particularly when the trial is being used to guide decisions about DRI, as opposed to decisions about whether to actively recommend supplementation for an individual woman.

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

# These items were explicitly described in Wactawski-Wenda et al. N Engl J Med 2006, which met the “y” criteria.

## Iso 1999

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
10471422 | Iso 1999 | Cohort study | Female nurses | Inadequate FFQ, implausible food intake, nonmelanoma cancer, CVD | 1980 | Nurses’ Health Study | NIH | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
10471422 | Iso 1999 | Cohort study | US, various | 86,368 | 85,764 | ~46 | (Probably 32–57) | 0 | White 98% | ~14% BMI ≥29 | Healthy | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
10471422 | Iso 1999 | Dietary calcium intake | FFQ | nd here | done elsewhere | NA | NA | | NA | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
10471422 | Iso 1999 | 1° | All stroke | Self-report, medical record review, death index etc, death certificates (standard definitions)
| | | also data for stroke types | not extracted

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
10471422 | Iso 1999 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
10471422 | Iso 1999 | Demographics (e.g., age, gender, race, education)? | Yes | Age
10471422 | Iso 1999 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No
10471422 | Iso 1999 | Medical conditions
10471422 | Iso 1999 | Medication
10471422 | Iso 1999 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
10471422 | Iso 1999 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | Smoking
10471422 | Iso 1999 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Median Ca intake | No. of Cases (Event) * | Total N | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups *** | P for trend ****
10471422 | Iso 1999 | Stroke | Calcium intake quintile 1 | | 395 | 165 | ~17153 | 14 y | Adjusted | RR | 1.0 | -- | -- | NS
| | | quintile 2 | | 645 | 132 | ~17153 | | | | 0.79 | 0.63, 1.00 | .05
| | | quintile 3 | | 675 | 117 | ~17153 | | | | 0.71 | 0.56, 0.90 | <.05
| | | quintile 4 | | 837 | 142 | ~17153 | | | | 0.87 | 0.70, 1.09 | NS
| | | quintile 5 | | 1145 | 134 | ~17153 | | | | 0.83 | 0.66, 1.04 | NS

Duplicate one row per exposure category or intervention group

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
10471422 | Iso 1999 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | implied | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Median only | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
10471422 | Iso 1999 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | Y | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Median only | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | ?
10471422 | Iso 1999 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | else-where | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | A
Explanation for Overall Quality Grade (if not Grade A): .

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Jacobs 2004

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
15225833 | Jacobs 2004 | Case-cohort study | Caucasian, male | nd | 1983, 1989 | Nutritional Prevention of Cancer (NPC) | National Cancer Institute | KP/SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake...etc.)
15225833 | Jacobs 2004 | Case- cohort study | Eastern United States (25°46′N to 41°41′N) | 1312 in original cohort, 249 with exposure and outcome data; 83 cases; 166 controls | 249 | 68 | nd | 100 | white | 26 | some subjects were on Se to prevent recurrence of non-melanoma skin cancer | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
15225833 | Jacobs 2004 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | RIA | Y, coefficient of variation for 1,25(OH) D = 11.5% and 25(OH)D = 12.9% | nd | nd | nd
| | Dietary calcium intake | nd | nd | nd | nd | nd | | nd | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
15225833 | Jacobs 2004 | secondary | Prostate cancer | nd

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
15225833 | Jacobs 2004 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
15225833 | Jacobs 2004 | Demographics (e.g., age, gender, race, education)? | Yes | age
15225833 | Jacobs 2004 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI
15225833 | Jacobs 2004 | Medical conditions
15225833 | Jacobs 2004 | Medication | Original treatment group (selenium or placebo)
15225833 | Jacobs 2004 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | Clinic site
15225833 | Jacobs 2004 | Smoking and other life styles variables | Yes | Cigarette smoking- pack years
15225833 | Jacobs 2004 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non- cases/Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
15225833 | Jacobs 2004 | Prostate cancer | Tertile 1: 25(OH)D = 8.1–25.3 ng/ml | Nd | Nd | 26 | 58 | adjusted | OR | 1.00 | reference | | 0.51
| | | Tertile 2: 25(OH)D = 25.4–32.7 ng/ml | Nd | Nd | 33 | 49 | | | 1.71 | 0.68–4.34
| | | Tertile 3: 25(OH)D = 32.8–59.7 ng/ml | Nd | Nd | 24 | 59 | | | 0.75 | 0.29–1.91
| | Prostate cancer | Tertile 1: 1,25(OH)D = 13.7– 27.5 ng/ml | Nd | Nd | 27 | 56 | adjusted | OR | 1.00 | reference | | 0.90
| | | Tertile 2: 1,25(OH)D = 27.6– 32.9 ng/ml | Nd | Nd | 29 | 54 | | | 1.44 | 0.59–3.52
| | | Tertile 3: 1,25(OH)D = 33.0– 64.4 ng/ml | Nd | Nd | 27 | 56 | | | 1.06 | 0.42–2.66

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers | | Comparator | | Statistical Analysis | | Outcome | | Design
15225833 | Jacobs 2004 | a) Eligibility criteria clear? (y/n) | n | a) Exposure assessor blinded to outcome info? (y/n) | nd | a) Method reported? (y/n) | NA | a) One of the prespecified methods *** was used? (y/n) | y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | a) Clear definition of outcome, including time of ascertainment? (y/n) | n | a) Prospective collection of data? (y/n) | y
15225833 | Jacobs 2004 | b) Sampling of population random or consecutive? (y/n) | N/A | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | NA | Time from sample collection to sample analysis reported? (y/n) | n | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | b) Loss to follow-up <20%? (y/n) | y | b) Analysis was planned when cohort was formed? (y/n) | nd
15225833 | Jacobs 2004 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | NA | | | | | b) Justification of final adjusted model selection? (y/n) | y | c) Do the authors specify a primary outcome? (y/n) | n | c) Justification of sample size (includes sample size calculations)? (y/n) | n
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Quite a few specifics left out, such as explanation of how cases were ascertained.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Jarvinen 2001

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
11641750 | Jarvinen 2001 | Cohort study | - Participant of a large-scale health examination survey; - Being interviewed to assess dietary intake (about 20%, unclear if consecutive); - Dietary data available and no previous cancer at baseline | nd | 1966–1972 | nd | nd | TTE

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
11641750 | Jarvinen 2001 | Cohort study | Finland (64 00 N) | 9959 | 9959 | 39.1 (nd) | 15- | nd | nd | BMI=24.8 kg/m2 | nd | Total energy=2602.6Kcal

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
11641750 | Jarvinen 2001 | Dietary calcium intake | Diet history Dietary survey (interview guided by questionnaire | Finnish food composition table (Rastas et al. 1989) | Y (interclass correlation coefficients 4–7 y apart) Dietary Ca: 0.53–0.55 Dietary Vit D: 0.42 | NA | NA | | nd | 1414 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
11641750 | Jarvinen 2001 | Not explicitly described | Colorectal cancer | Finish cancer registry (ICD153-154 [WHO 1955]); unclear about confirmation by other sources
| | Not explicitly described | Colon cancer | Finish cancer registry (no clear definition)
| | Not explicitly described | Rectal cancer | Finish cancer registry (no clear definition)

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
11641750 | Jarvinen 2001 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes (Dietary energy intake) | Folic acid, fiber taken into account in sensitivity analysis but the results not reported.
11641750 | Jarvinen 2001 | Demographics (e.g., age, gender, race, education)? | Yes (Age, sex)
11641750 | Jarvinen 2001 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes (BMI)
11641750 | Jarvinen 2001 | Medical conditions | no
11641750 | Jarvinen 2001 | Medication | No
11641750 | Jarvinen 2001 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | Yes (geographical region)
11641750 | Jarvinen 2001 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes (smoking, occupation)
11641750 | Jarvinen 2001 | Other | | Cancer during the first-year f/u excluded in sensitivity analysis but the results not reported.

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean follow-up time | Mean Ca dose (mg) | No. of Cases (Event) * | No. of Non-cases/Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups *** | P for trend ****
11641750 | Jarvinen 2001 | Colorectal cancer (total Ca [mg]) | Q1 | 19.6 y | M: <1178.2 F: <862.5 | 20 | Nd | Adjusted | RR (HR) | 1.00 | Ref | Nd | 0.97
| | | Q2 | | M: 1178.2–1557.1 F: 862.5–1110.7 | 19 | nd | | | 1.17 | 0.60–2.27 | nd
| | | Q3 | | M: 1557.2–1953.2 F: 1110.8–1416.6 | 18 | Nd | | | 1.37 | 0.67–2.81 | nd
| | | Q4 | | M: 1953.3- F: 1416.7- | 15 | nd | | | 1.43 | 0.61–3.39 | nd
11641750 | Jarvinen 2001 | Colon cancer (total Ca [mg]) | Q1 | 19.6 y | M: <1178.2 F: <862.5 | 10 | Nd | Adjusted | RR (HR) | 1.00 | Ref | Nd | 0.17
| | | Q2 | | M: 1178.2–1557.1 F: 862.5–1110.7 | 14 | nd | | | 1.44 | 0.61–3.39 | nd
| | | Q3 | | M: 1557.2–1953.2 F: 1110.8–1416.6 | 9 | Nd | | | 1.04 | 0.38–2.83 | nd
| | | Q4 | | M: 1953.3- F: 1416.7- | 5 | nd | | | 0.63 | 0.17–2.35 | nd
11641750 | Jarvinen 2001 | Rectal cancer (total Ca [mg]) | Q1 | 19.6 y | M: <1178.2 F: <862.5 | 10 | Nd | Adjusted | RR (HR) | 1.00 | ref | Nd | 0.19
| | | Q2 | | M: 1178.2–1557.1 F: 862.5–1110.7 | 5 | nd | | | 0.77 | 0.25–2.37 | nd
| | | Q3 | | M: 1557.2–1953.2 F: 1110.8–1416.6 | 9 | Nd | | | 1.88 | 0.67–5.30 | nd
| | | Q4 | | M: 1953.3- F: 1416.7- | 10 | nd | | | 3.01 | 0.93–9.73 | nd

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

MEAN DATA

THIS SHOULD ONLY APPLY TO CASE-COHORT STUDIES THAT COMPARE BASELINE VIT D/CA LEVELS BETWEEN CASES (WITH DISEASE) AND CONTROLS (WITHOUT DISEASE)

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Mean 25(OH)D Level | Vit D level CI/SE/SD* | Mean Ca intake or Ca balance | Ca CI/SE/SD* | P between groups
11641750 | Jarvinen 2001 | Cases: colorectal cancer | 19.6 y | Adjusted (age and sex) | 72 | Nd | Nd | 1335 | Nd | 0.24
| | Control: | | | 9887 | nd | nd | 1415 | Nd

Duplicate one table per outcome

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
11641750 | Jarvinen 2001 | a) Eligibility criteria clear? (y/n) | y | a) Exposure assessor blinded to outcome info? (y/n) | nd | a) Method reported? (y/n) | y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders(other than age and sex)? ** (y/n) | y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
11641750 | Jarvinen 2001 | b) Sampling of population random or consecutive? (y/n) | n | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders(other than age and sex)? ** (y/n) | y | b) Loss to follow-up<20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
11641750 | Jarvinen 2001 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | y | | NA | | | b) Justification of final adjusted model selection? (y/n) | n | c) Do the authors specify a primary outcome? (y/n) | n | c) Justification of sample size (includes sample size calculations)? (y/n) | n
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Unclear consecutiveness, some poor reporting, post-hoc analysis of an existing database; power calculation not reported; diet history instead of FFQ used for calcium assessment; case confirmation by histology not reported

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Jia 2007

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17442130 | Jia 2007 | Cohort study | 75 y or older | Terminal illness Severe dementia | 1999–2000 | nd | nd | TTe

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
17442130 | Jia 2007 | Cohort study | Aberdeen, UK | 405 | 398 | 80 ^ # ^ | Range 75–96 | 52 | nd | BMI: median 25.4 kg/m ^ 2 ^ , range (23.4–27.7) | - 58% heart disease (self report); - 6% DM (self report); - 85% fair to very good health status (self-perception); - 44% no physical activity | 27% took Vit D supplement 74% had 2 or more portions of fruits or vegetables

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

# median

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
17442130 | Jia 2007 | 25(OH)D | | | | “RIA” | n | Nd (~6 to ~7 y) (Median f/u of the entire cohort: 69.2 mon [range, 1.0–79.9]) | April 1999 and March 2000 # | nd
17442130 | Jia 2007 | Dietary calcium intake | nd | nd | nd | nd | nd | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

# Excerpts from the paper on original cohort study (McNeill Br J Nutr 2002) “For the subjects seen in summer (June–September), repeat samples were taken in winter (February–March) to estimate seasonal change in vitamin D status.” In this report, it is unclear if such data are available or not.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17442130 | Jia 2007 | primary | mortality | Mortality from any causes

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17442130 | Jia 2007 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | No | See the hierarchy of the planned model below
17442130 | Jia 2007 | Demographics (e.g., age, gender, race, education)? | Yes | See the hierarchy of the planned model below
17442130 | Jia 2007 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No | See the hierarchy of the planned model below
17442130 | Jia 2007 | Medical conditions | Yes | See the hierarchy of the planned model below
17442130 | Jia 2007 | Medication | Yes | See the hierarchy of the planned model below
17442130 | Jia 2007 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | Yes | See the hierarchy of the planned model below
17442130 | Jia 2007 | Smoking and other life styles variables | Yes | See the hierarchy of the planned model below
17442130 | Jia 2007 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

Model 1: age, sex

Model 2: age, sex, (self-perceived) health status, taking 5 or more kinds of medication

Model 3: age, sex, (self-perceived) health status, taking 5 or more kinds of medication, (self-reported) heart disease, (self-reported) diabetes

Model 4: age, sex, (self-perceived) health status, taking 5 or more kinds of medication, (self-reported) heart disease, (self-reported) diabetes, sunlight exposure

Model 5: age, sex, (self-perceived) health status, taking 5 or more kinds of medication, (self-reported) heart disease, (self-reported) diabetes, Vit D supplement

Model 6: age, sex, (self-perceived) health status, taking 5 or more kinds of medication, (self-reported) heart disease, (self-reported) diabetes, sunlight exposure, Vit D supplement

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level (nmol/L) | Mean Ca level/dose | No. of Cases (Event) * | Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/ ** | P between groups *** | P for trend ****
17442130 | Jia 2007 | Mortality | Q1 | 6.0–23.0 (M)/7.0–19.0 (F) | nd | 41 | 75 | Adjusted (Model 1) | HR | 2.89 | 1.61–5.18 | nd | <0.001
17442130 | Jia 2007 | Mortality | Q2 | 23.1–30.0 (M)/29.1–24.0 (F) | nd | 34 | 86 | Adjusted (Model 1) | HR | 2.07 | 1.14–3.76 | nd | <0.001
17442130 | Jia 2007 | Mortality | Q3 | 30.1–37.0 (M)/24.1–30.2 (F) | nd | 21 | 80 | Adjusted (Model 1) | HR | 1.16 | 0.60–2.24 | nd | <0.001
17442130 | Jia 2007 | Mortality | Q4 | 37.1–47.0 (M)/30.3–39.0 (F) | nd | 17 | 78 | Adjusted (Model 1) | HR | 1.0 | 0.50–1.97 | nd | <0.001
17442130 | Jia 2007 | Mortality | Q5 | 47.1–82.0 (M)/39.1–82.0 (F) | nd | 16 | 79 | Adjusted (Model 1) | HR | reference | - | nd | <0.001
17442130 | Jia 2007 | Mortality | Q1 | 6.0–23.0 (M)/7.0–19.0 (F) | nd | 41 | 75 | Adjusted (Model 2) | HR | 2.22 | 1.21–4.07 | nd | 0.003
17442130 | Jia 2007 | Mortality | Q2 | 23.1–30.0 (M)/29.1–24.0 (F) | nd | 34 | 86 | Adjusted (Model 2) | HR | 1.71 | 0.93–3.14 | nd | 0.003
17442130 | Jia 2007 | Mortality | Q3 | 30.1–37.0 (M)/24.1–30.2 (F) | nd | 21 | 80 | Adjusted (Model 2) | HR | 1.03 | 0.53–2.02 | nd | 0.003
17442130 | Jia 2007 | Mortality | Q4 | 37.1–47.0 (M)/30.3–39.0 (F) | nd | 17 | 78 | Adjusted (Model 2) | HR | 0.96 | 0.48–1.92 | nd | 0.003
17442130 | Jia 2007 | Mortality | Q5 | 47.1–82.0 (M)/39.1–82.0 (F) | nd | 16 | 79 | Adjusted (Model 2) | HR | reference | - | nd | 0.003
17442130 | Jia 2007 | Mortality | Q1 | 6.0–23.0 (M)/7.0–19.0 (F) | nd | 41 | 75 | Adjusted (Model 3) | HR | 2.22 | 1.22–4.06 | nd | 0.001
17442130 | Jia 2007 | Mortality | Q2 | 23.1–30.0 (M)/29.1–24.0 (F) | nd | 34 | 86 | Adjusted (Model 3) | HR | 1.75 | 0.95–3.22 | nd | 0.001
17442130 | Jia 2007 | Mortality | Q3 | 30.1–37.0 (M)/24.1–30.2 (F) | nd | 21 | 80 | Adjusted (Model 3) | HR | 1.03 | 0.53–2.00 | nd | 0.001
17442130 | Jia 2007 | Mortality | Q4 | 37.1–47.0 (M)/30.3–39.0 (F) | nd | 17 | 78 | Adjusted (Model 3) | HR | 0.92 | 0.46–1.84 | nd | 0.001
17442130 | Jia 2007 | Mortality | Q5 | 47.1–82.0 (M)/39.1–82.0 (F) | nd | 16 | 79 | Adjusted (Model 3) | HR | reference | - | nd | 0.001
17442130 | Jia 007 | Mortality | Q1 | 6.0–23.0 (M)/7.0–19.0 (F) | nd | 41 | 75 | Adjusted (Model 4) | HR | 2.02 | 1.10–3.72 | nd | 0.008
17442130 | Jia 007 | Mortality | Q2 | 23.1–30.0 (M)/29.1–24.0 (F) | nd | 34 | 86 | Adjusted (Model 4) | HR | 1.64 | 0.89–3.02 | nd | 0.008
17442130 | Jia 007 | Mortality | Q3 | 30.1–37.0 (M)/24.1–30.2 (F) | nd | 21 | 80 | Adjusted (Model 4) | HR | 1.01 | 0.52–1.96 | nd | 0.008
17442130 | Jia 007 | Mortality | Q4 | 37.1–47.0 (M)/30.3–39.0 (F) | nd | 17 | 78 | Adjusted (Model 4) | HR | 0.87 | 0.43–0.75 | nd | 0.008
17442130 | Jia 007 | Mortality | Q5 | 47.1–82.0 M)/39.1–82.0 (F) | nd | 16 | 79 | Adjusted (Model 4) | HR | reference | - | nd | 0.008
17442130 | Jia 2007 | Mortality | Q1 | 6.0–23.0(M)/7.0–19.0 (F) | nd | 41 | 75 | Adjusted (Model 5) | HR | 1.97 | 1.03–3.75 | nd | 0.01
17442130 | Jia 2007 | Mortality | Q2 | 23.1–30.0 (M)/29.1–24.0 (F) | nd | 34 | 86 | Adjusted (Model 5) | HR | 1.54 | 0.80–2.97 | nd | 0.01
17442130 | Jia 2007 | Mortality | Q3 | 30.1–37.0 (M)/24.1–30.2 (F) | nd | 21 | 80 | Adjusted (Model 5) | HR | 0.95 | 0.48–1.88 | nd | 0.01
17442130 | Jia 2007 | Mortality | Q4 | 37.1–47.0 (M)/30.3–39.0 (F) | nd | 17 | 78 | Adjusted (Model 5) | HR | 0.86 | 0.43–1.74 | nd | 0.01
17442130 | Jia 2007 | Mortality | Q5 | 47.1–82.0 (M)/39.1–82.0 (F) | nd | 16 | 79 | Adjusted (Model 5) | HR | reference | - | nd | 0.01
17442130 | Jia 2007 | Mortality | Q1 | 6.0–23.0 (M)/7.0–19.0 (F) | nd | 41 | 75 | Adjusted (Model 6) | HR | 1.74 | 0.91–3.34 | nd | 0.03
17442130 | Jia 2007 | Mortality | Q2 | 23.1–30.0 (M)/29.1–24.0 (F) | nd | 34 | 86 | Adjusted (Model 6) | HR | 1.40 | 0.73–2.70 | nd | 0.03
17442130 | Jia 2007 | Mortality | Q3 | 30.1–37.0 (M)/24.1–30.2 (F) | nd | 21 | 80 | Adjusted (Model 6) | HR | 0.90 | 0.45–1.79 | nd | 0.03
17442130 | Jia 2007 | Mortality | Q4 | 37.1–47.0 (M)/30.3–39.0 (F) | nd | 17 | 78 | Adjusted (Model 6) | HR | 0.80 | 0.39–1.62 | nd | 0.03
17442130 | Jia 2007 | Mortality | Q5 | 47.1–82.0 (M)/39.1–82.0 (F) | nd | 16 | 79 | Adjusted (Model 6) | HR | reference | - | nd | 0.03

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

Model 1: age, sex

Model 2: age, sex, (self-perceived) health status, taking 5 or more kinds of medication

Model 3: age, sex, (self-perceived) health status, taking 5 or more kinds of medication, (self-reported) heart disease, (self-reported) diabetes

Model 4: age, sex, (self-perceived) health status, taking 5 or more kinds of medication, (self-reported) heart disease, (self-reported) diabetes, sunlight exposure

Model 5: age, sex, (self-perceived) health status, taking 5 or more kinds of medication, (self-reported) heart disease, (self-reported) diabetes, Vit D supplement

Model 6: age, sex, (self-perceived) health status, taking 5 or more kinds of medication, (self-reported) heart disease, (self-reported) diabetes, sunlight exposure, Vit D supplement

MEAN DATA

THIS SHOULD ONLY APPLY TO CASE-COHORT STUDIES THAT COMPARE BASELINE VIT D/CA LEVELS BETWEEN CASES (WITH DISEASE) AND CONTROLS (WITHOUT DISEASE)

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Mean 25(OH)D Level | Vit D level CI/SE/SD* | Mean Ca intake or Ca balance | Ca CI/SE/SD* | P between groups
17442130 | Jia 2007 | Cases: | Nd (~6 to ~7 y) (Median f/u: 69.2 mon [range, 1.0–79.9]) | Crude | 129 | 26.0 ^ # ^ | 6.0–63.0 ^ # ^ | Nd | nd | <0.001 (Mann- Whitney)
17442130 | Jia 2007 | Control: | Nd (~6 to ~7 y) (Median f/u: 69.2 mon [range, 1.0–79.9]) | Crude | 269 | 33.0 ^ # ^ | 9.0–82.0 ^ # ^ | nd | Nd | <0.001 (Mann- Whitney)

Duplicate one table per outcome

# Median with range. Convert this into mean by using the method by Hozo (Hozo et al. 2008)

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level (nmol/L) | Mean Ca level/dose | No. of Cases (Event)* | Total N** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/** | P between groups*** | P for trend****
17442130 | Jia 2007 | Mortality (Men only) | Q1 | 6.0–23.0 | nd | 21 | 38 | Adjusted (Model 3) | HR | 2.02 | 0.88–4.65 | nd | 0.02
17442130 | Jia 2007 | Mortality (Men only) | Q2 | 23.1–30.0 | nd | 21 | 49 | Adjusted (Model 3) | HR | 1.89 | 0.84–4.27 | nd | 0.02
17442130 | Jia 2007 | Mortality (Men only) | Q3 | 30.1–37.0 | nd | 11 | 39 | Adjusted (Model 3) | HR | 0.99 | 0.40–2.50 | nd | 0.02
17442130 | Jia 2007 | Mortality (Men only) | Q4 | 37.1–47.0 | nd | 9 | 39 | Adjusted (Model 3) | HR | 0.91 | 0.35–2.36 | nd | 0.02
17442130 | Jia 2007 | Mortality (Men only) | Q5 | 47.1–82.0 | nd | 9 | 42 | Adjusted (Model 3) | HR | reference | - | nd | 0.02
17442130 | Jia 2007 | Mortality (Women only) | Q1 | 7.0–19.0 | nd | 20 | 37 | Adjusted (Model 3) | HR | 2.71 | 1.12–6.58 | nd | 0.02
17442130 | Jia 2007 | Mortality (Women only) | Q2 | 29.1–24.0 | nd | 13 | 37 | Adjusted (Model 3) | HR | 1.60 | 0.63–4.06 | nd | 0.02
17442130 | Jia 2007 | Mortality (Women only) | Q3 | 24.1–30.2 | nd | 10 | 41 | Adjusted (Model 3) | HR | 1.08 | 0.41– 2.89 | nd | 0.02
17442130 | Jia 2007 | Mortality (Women only) | Q4 | 30.3–39.0 | nd | 8 | 39 | Adjusted (Model 3) | HR | 0.97 | 0.35–2.69 | nd | 0.02
17442130 | Jia 2007 | Mortality (Women only) | Q5 | 39.1–82.0 | nd | 7 | 37 | Adjusted (Model 3) | HR | reference | - | nd | 0.02

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
17442130 | Jia 2007 | a) Eligibility criteria clear? (y/n) | y | a) Exposure assessor blinded to outcome info? (y/n) | Nd | a) Method reported? (y/n) | n/NA | a) One of the prespecified methods *** was used? (y/n) | y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | a) Clear definition of outcome, including time of ascertainment? (y/n) | y | a) Prospective collection of data? (y/n) | y
17442130 | Jia 2007 | b) Sampling of population random or consecutive? (y/n) | nd | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | n/NA | Time from sample collection to sample analysis reported? (y/n) | y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | b) Loss to follow-up <20%? (y/n) | y | b) Analysis was planned when cohort was formed? (y/n) | nd
17442130 | Jia 2007 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | NA | | | | | b) Justification of final adjusted model selection? (y/n) | n | c) Do the authors specify a primary outcome? (y/n) | y | c) Justification of sample size (includes sample size calculations)? (y/n) | y
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): . | | | | | | | No details on enrollment and blinding assessment, some may have been excluded due to unavailability of data (e.g., blood sample), leading to the possibility of selection bias

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Johnson 1994

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
8201444 | Johnson 1994 | Cohort study | African American women; 16–35 y; pregnant; nulliparity | DM, sickle cell, thalassemia, Hb C | nd | | NICHD | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
8201444 | Johnson 1994 | Cohort study | Washington DC | 322 | 322 | 21.6 | 16->31 (est.) | 0 | African American | 42% 90–110% of ideal prepregnancy body weight; 28% >120% of ideal prepregnancy body weight | nd | Calcium 933.4 ± 51.8 (SE) mg/d intake

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
8201444 | Johnson 1994 | Dietary calcium intake | FFQ | USDA | n | | | | | Calcium 933.4 ± 51.8 (SE) mg/d intake

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
8201444 | Johnson 1994 | primary | birth weight
| | | birth length
| | | gestational age

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
8201444 | Johnson 1994 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
8201444 | Johnson 1994 | Demographics (e.g., age, gender, race, education)? | no *
8201444 | Johnson 1994 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no *
8201444 | Johnson 1994 | Medical conditions
8201444 | Johnson 1994 | Medication
8201444 | Johnson 1994 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
8201444 | Johnson 1994 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no *
8201444 | Johnson 1994 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
8201444 | Johnson 1994 | birth weight; birth length | “None of the food energy and nutrient intakes was significantly correlated with any of the pregnancy outcome measures”. No specific quantitative relationship was provided for calcium.

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
8201444 | Johnson 1994 | a) Eligibility criteria clear? (y/n) | y | a) Exposure assessor blinded to outcome info? (y/n) | n | a) Method reported? (y/n) | y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | n | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | nd | a) Clear definition of outcome, including time of ascertainment? (y/n) | y | a) Prospective collection of data? (y/n) | y
8201444 | Johnson 1994 | b) Sampling of population random or consecutive? (y/n) | nd | b) Outcome assessor blinded to exposure measurement? (y/n) | n | b) Food composition database or suppl composition reported? (y/n) | n | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | n | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | nd | b) Loss to follow-up <20%? (y/n) | y | b) Analysis was planned when cohort was formed? (y/n) | y
8201444 | Johnson 1994 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | n | | | | | b) Justification of final adjusted model selection? (y/n) | nd | c) Do the authors specify a primary outcome? (y/n) | y | c) Justification of sample size (includes sample size calculations)? (y/n) | n
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | incomplete presentation of analysis

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Kabrnova-Hlavata 2008

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17552880 | Kabrnova-Hlavata 2008 | Other intervention study | -overweight or obese -female | -diabetes -uncompensated thyroid dysfunction -drugs affecting water balance | nd | none | Supported by grants IGA NR/7800- 4 and S-QF 3166 | MB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
17552880 | Kabrnova-Hlavata 2008 | Other intervention study | Prague, Czech Republic. 50 N | 67 | 67 | 49.1±12.1 | nd | 0% | nd | BMI=32.2±4.1 Weight=84.5±13 %body fat=41.5±5.5 | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
17552880 | Kabrnova-Hlavata 2008 | 25(OH)D and/or 1,25(OH) _ 2 _ D
| | Dietary calcium intake | nd | nd | nd | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
17552880 | Kabrnova-Hlavata 2008 | placebo | Food/tablets | 350 mg/d from food | 3 wks | Placebo tablets were taken 3x/day
| | Ca | Calcium carbonate + food | 500 mg/d tablet/350 mg/d from food | 3 wks | Tablets were taken 3x/day
| | Ca | Lactoval (70% Ca phosphate, 20% Ca citrate, 10% Ca lactate) | 500 mg/d tablet/350 mg/d from food | 3 wks | Tablets were taken 3x/day
Co-intervention(s) * : | | | Only those subjects who exhibited a stable weight during 1 week on 7 MJ/d diet entered the trial and received a 4.5 MJ/day diet for the next 3 weeks (diet supplied 350 mg/d Ca) plus tablets.
Compliance/Adherence: | | | All subjects were advised to eat all the meals served in four daily portions in the spa dining room. A dietician checked that subjects took tablets.

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17552880 | Kabrnova-Hlavata 2008 | nd | weight | Analyzed by a bipedal-bimanual Body Composition Analyzer Tanita BC-418MA
| | nd | BMI

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17552880 | Kabrnova-Hlavata 2008 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes | All three groups on 7 MJ/day diet
17552880 | Kabrnova-Hlavata 2008 | Demographics (e.g., age, gender, race, education)? | Yes | All three groups matched on age
17552880 | Kabrnova-Hlavata 2008 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | Groups matched on BMI and % body fat
17552880 | Kabrnova-Hlavata 2008 | Medical conditions | No
17552880 | Kabrnova-Hlavata 2008 | Medication | No
17552880 | Kabrnova-Hlavata 2008 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | No
17552880 | Kabrnova-Hlavata 2008 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | No
17552880 | Kabrnova-Hlavata 2008 | Other | “The studied women were predominantly perimenopausal. The number of women in menopause was comparable in the groups.”

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure Category/Intervention Group | Crude or Adjusted analysis ? | Mean Follow-up (months) | No. Analyzed | Baseline | Baseline SD * | Delta ** | Delta SD | Net difference *** | Net difference CI/SE/SD * | P between groups ***
17552880 | Kabrnova-Hlavata 2008 | Weight | kg | placebo | Adjusted | 3 wks | 21 | 85.37 | 14.83 | −4.34 | 1.37 | | | NS
| | | | Ca carbonate | Adjusted | 3 wks | 25 | 84.95 | 11.75 | −3.34 | 1.79 | | | NS
| | | | Lactoval | Adjusted | 3 wks | 21 | 83.43 | 11.65 | −3.87 | 1.62 | | | NS
| | BMI | Kg/m ^ 2 ^ | placebo | Adjusted | 3 wks | 21 | 32.36 | 4.86 | −1.64 | 0.49 | | | NS
| | | | Ca carbonate | Adjusted | 3 wks | 25 | 32.39 | 4.35 | −1.29 | 0.69 | | | NS
| | | | Lactoval | Adjusted | 3 wks | 21 | 32.42 | 4.22 | −1.51 | 0.65 | | | NS

Duplicate one row per exposure category or intervention group. Please write “nd” if there was no data reported. DO NOT LEAVE BLANK.

* Please choose one and delete the others

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
17552880 | Kabrnova-Hlavata 2008 | Non- randomized controlled trial | NA | NA | NA | N | nd | nd | Y | Y | Y | B
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Nd on how subjects were divided into groups

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT– Parallel, RCT– Cross-over, RCT– Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Kampman 1994

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
8205538 | Kampman 1994 | Cohort study | - Age 55 to 69 participant of Netherlands Cohort Study on diet and cancer (n=120852); - Subpopulation randomly selected from the main cohort (n=3500) | - History of cancer (excluding skin cancer) (n=154); - Incomplete/inconsistent dietary data (n=235); - Events (cancer only?) within the first year of follow-up (n=28) | 1986 | Netherlands Cohort Study on diet and cancer | Netherlands Digestive Diseases Foundation, Dutch Cancer Society | TTE

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
8205538 | Kampman 1994 | Cohort study | Netherlands (nd) (52 30 N) | 3500 (see above) | 3111 | ~61 (nd) # | 55–69 (per inclusion criteria) | ~49% # | nd | nd | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

# approximated based on the data on the highest and lowest quintile of Ca intake.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
8205538 | Kampman 1994 | Dietary calcium intake | 150 item-FFQ | nd | N | | | | | Ca=1286 mg/d (energy- adjusted median)

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
8205538 | Kampman 1994 | nd | Colorectal cancer | Record linkage to cancer registries and a nationwide pathology registry

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
8205538 | Kampman 1994 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes (any vitamin suppl. use, energy, energy- adjusted intake of fat and dietary fiber)
8205538 | Kampman 1994 | Demographics (e.g., age, gender, race, education)? | Yes (age, gender, level of education)
8205538 | Kampman 1994 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No
8205538 | Kampman 1994 | Medical conditions | Yes (Hx of gallbladder surgery)
8205538 | Kampman 1994 | Medication | No
8205538 | Kampman 1994 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | No
8205538 | Kampman 1994 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes (smoking)
8205538 | Kampman 1994 | Other | Family history of colorectal cancer

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death) After excluding first year of follow up

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean follow- up time, mo | Median Ca dose | No. of Cases (Event) * | No. of Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
8205538 | Kampman 1994 | Colorectal cancer (Total Ca [mg]) | Q1 | 39.6 | 596 | 98 | 623 | Adjusted (age, gender, energy) | RR | 1.00 | Ref | | 0.87
| | | Q2 | 39.6 | 768 | 89 | 619 | | RR | 0.83 | nd
| | | Q3 | 39.6 | 893 | 87 | 622 | | RR | 0.96 | nd
| | | Q4 | 39.6 | 1032 | 81 | 627 | | RR | 0.92 | nd
| | | Q5 | 39.6 | 1288 | 88 | 620 | | RR | 0.92 | nd
8205538 | Kampman 1994 | Colorectal cancer (Total Ca [mg]) | Q1 | 39.6 | 596 | 98 | 623 | Adjusted (full multivariate model) | RR | 1.00 | Ref | | 0.89
| | | Q2 | 39.6 | 768 | 89 | 619 | | RR | 0.83 | 0.58, 1.22
| | | Q3 | 39.6 | 893 | 87 | 622 | | RR | 0.96 | 0.67, 1.39
| | | Q4 | 39.6 | 1032 | 81 | 627 | | RR | 0.93 | 0.64, 1.36
| | | Q5 | 39.6 | 1288 | 88 | 620 | | RR | 0.92 | 0.64, 1.34

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
8205538 | Kampman 1994 | Ca intake from non-dairy products, fermented dairy products, unfermented dairy products were presented as subgroup analysis but only brief results (energy adjusted analyses) Ca from non-dairy products only: age-gender adjusted RR trend (Q1 vs. Q5) P=0.18; full multivariate adjusted RR (Q1 vs. Q5) trend P=0.01 Ca from fermented dairy products only: age-gender adjusted RR trend (Q1 vs. Q5) P=0.52; full multivariate adjusted RR trend (Q1 vs. Q5) P=0.32 Ca from non-fermented dairy products only: age-gender adjusted RR trend (Q1 vs. Q5) P=0.10; full multivariate adjusted RR trend (Q1 vs. Q5) P=0.11 Data on other exposures (fermented milk, hard cheese, unfermented milk) presented but not extracted.

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
8205538 | Kampman 1994 | a) Eligibility criteria clear? (y/n) | N | a) Exposure assessor blinded to outcome info? (y/n) | nd | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
8205538 | Kampman 1994 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | nd
8205538 | Kampman 1994 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | N | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Dietary calcium intake only was evaluated. Possibility of post-hoc analysis. Power calculation not reported; assessor blinding not reported; results without excluding 1 ^ st ^ year of follow up are not given; power calculation not reported

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Kato 1997

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
9343837 | Kato 1997 | Cohort study | - Women breast exam participants aged 34–65; - No hormonal medications or pregnancy for 6 mo prior to the enrollment; - 30 ml blood donation and answering a baseline questionnaire | - Prior colorectal cancer (n=58); - 8 or more blanks in the questionnaire (n=1000) | 1985–1991 | New York Univ. Women’s Health Study | NCI | TTe

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake...etc.)
9343837 | Kato 1997 | Cohort study | New York City, NY (40° 47′) or Lauderhill, FL (26° 8′) | 14727 | 14727 | nd | nd | 0% | [Based on only 11573 participants] Caucasian: 82% Black: 10% Hispanic: 5% Others: 3% | nd | [based on only 14724 participants] Aspirin use (last 4 wks): 25% | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
9343837 | Kato 1997 | Dietary calcium intake | 70-item FFQ slightly modified from Block’s | nd | Only n=267 assessed; Short term (2–3 mo): correlation coefficient=0.56, Long-term (2–5 y): “somewhat lower” | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
9343837 | Kato 1997 | Not explicitly stated but the only outcome reported | Colorectal Cancer | Self reports (in the questionnaires sent until the end of 1994) confirmed by medical records pathology reports, supplemented by the state cancer registries and the National Death Index

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
9343837 | Kato 1997 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes (total energy intake)
9343837 | Kato 1997 | Demographics (e.g., age, gender, race, education)? | Yes (age, education)
9343837 | Kato 1997 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No
9343837 | Kato 1997 | Medical conditions | No
9343837 | Kato 1997 | Medication | No
9343837 | Kato 1997 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | Yes (place of enrollment [i.e., NY vs. FL])
9343837 | Kato 1997 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | No
9343837 | Kato 1997 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D | Mean Ca level/dose | No. of Cases (Event) * | No. of Non- cases/Total N ** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups *** | P for trend ****
9343837 | Kato 1997 | Colorectal cancer (total Ca [mg]) | Q1 | nd | nd | nd | nd | 85.2 | adjusted | HR | 1.0 | Ref | nd | 0.178
| | | Q2 | nd | nd | nd | nd | 85.2 | | | 1.15 | 0.67–1.95 | nd
| | | Q3 | nd | nd | nd | nd | 85.2 | | | 0.90 | 0.52–1.57 | nd
| | | Q4 | nd | nd | nd | nd | 85.2 | | | 0.71 | 0.39–1.28 | nd

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
9343837 | Kato 1997 | a) Eligibility criteria clear? (y/n) | nd | a) Exposure assessor blinded to outcome info? (y/n) | nd | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | N | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
9343837 | Kato 1997 | b) Sampling of population random or consecutive? (y/n) | nd | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | N | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | nd | b) Analysis was planned when cohort was formed? (y/n) | N
9343837 | Kato 1997 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Y | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | N | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Study not designed initially for assessing calcium intake and CRC; power calculation not reported. Poor reporting throughout the paper precluded detailed assessments. Post-hoc analysis. Calcium intake per category not reported; blinding not reported

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Kearney 1996

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
8610704 | Kearney 1996 | Cohort study | - Male health professionals; - Age 40–75 in 1986; - Responded baseline questionnaire (n=51529) | Implausibly high (4200-)/low (−800) total energy intake (kcal/d) or failed to fill in the dietary assessment (n=49999) Precious cancer (excl. nonmelanoma skin cancer), ulcerative colitis, familial polyposis syndrome (n=47935) | 1986 | The Health Professionals Follow-up Study | American Cancer Society, NIH, National Dairy Council | TTe

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
8610704 | Kearney 1996 | Cohort study | US (25 46”– 54 40”N) | 47935 | 47239 | nd | 40–75 | 100% | nd | BMI=25kg/m2 | Family history=8.4% Previous polyps=3.6% Current activity=19.6 MET Current smoker=10.0% | Total energy intake=1958.7 kcal/d Fiber=23.0 g/d Saturated fat=25.2 g/d Ca=947.0 mg/d Vit D=400.9IU/d

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
8610704 | Kearney 1996 | Dietary calcium intake | FFQ (Rim et al. 1992) | USDA and others (Rim et al. 1992) | Correlation of coefficient (energy adjusted): 0.53 (before week- to-week variability adjusted) 0.60 (with supple) and 0.61 (without supple) (after week-to-week variability adjusted) | | | | | Ca=947.0 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
8610704 | Kearney 1996 | nd | Colon caner | Response to the biennial questionnaires confirmed by the hospital/pathology reports or the National Death Index. During the 6-year follow-up.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
8610704 | Kearney 1996 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes (red meat, saturated fat, fiber, vitamin E)
8610704 | Kearney 1996 | Demographics (e.g., age, gender, race, education)? | Yes (age)
8610704 | Kearney 1996 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes (BMI)
8610704 | Kearney 1996 | Medical conditions | Yes (family history of colon cancer, previous polyps, prior screening)
8610704 | Kearney 1996 | Medication | Yes (aspirin)
8610704 | Kearney 1996 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | No
8610704 | Kearney 1996 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes (smoking, alcohol, physical activity)
8610704 | Kearney 1996 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Ca dose | No. of Cases (Event) * | No. of Person- years ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
8610704 | Kearney 1996 | Colon cancer (total Ca intake [mg]) | Q1 | “6 y” | <631 | 59 | 51343 | Adjusted (age, energy intake) | OR | 1.0 | Ref | nd | 0.01
| | | Q2 | | 631–765 | 32 | 51501 | | | 0.57 | 0.36– 0.85 | nd
| | | Q3 | | 766–921 | 36 | 51127 | | | 0.60 | 0.39– 0.90 | nd
| | | Q4 | | 922– 1212 | 37 | 52047 | | | 0.61 | 0.40– 0.89 | nd
| | | Q5 | | 1213– | 39 | 51620 | | | 0.58 | 0.39– 0.87 | nd
8610704 | Kearney 1996 | Colon cancer (total Ca intake [mg]) | Q1 | “6 y” | <631 | 59 | 51343 | Adjusted (full multivariate model) | RR (OR) | 1.0 | Ref | nd | 0.22
| | | Q2 | | 631– 765 | 32 | 51501 | | | 0.64 | 0.42– 1.01 | nd
| | | Q3 | | 766– 921 | 36 | 51127 | | | 0.73 | 0.47– 1.12 | nd
| | | Q4 | | 922– 1212 | 37 | 52047 | | | 0.74 | 0.48– 1.15 | nd
| | | Q5 | | 1213– | 39 | 51620 | | | 0.75 | 0.48– 1.15 | nd

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
8610704 | Kearney 1996 | 1. Ca intake from food (dietary Ca), dairy products, and non-dairy products were presented as subgroup analysis but only brief results:; - Dietary Ca: age-gender adjusted RR trend P=0.02; full multivariate adjusted RR trend P=0.62; - Ca from dairy products only: age-energy adjusted RR trend P=0.001; full multivariate adjusted RR trend P=0.28; - Ca from non-dairy products only: age-energy adjusted RR trend P=0.06; full multivariate adjusted RR trend P=0.30; 2. Data on Vit D intake without blood Vit D level presented but not extracted (ineligible).

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
8610704 | Kearney 1996 | a) Eligibility criteria clear? (y/n) | N | a) Exposure assessor blinded to outcome info? (y/n) | nd | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
| | b) Sampling of population random or consecutive? (y/n) | nd | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
| | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Y | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | N | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Some unclear reporting (eligibility, blinding), post-hoc analysis, some important confounders (e.g., Vit D) not fully taken into account.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Kesse 2005

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
15880532 | Kesse 2005 | Cohort study | Women living in France, aged 40 to 65 years at baseline and insured with the Mutuelle Générale de l’Education Nationale, a national health insurance scheme for teachers. | Subjects who had reported a cancer diagnosis before the start of follow-up, non- histologically confirmed colorectal cancer, a familial polyposis syndrome, an inflammatory bowl disease, lost to follow-up after dietary assessment | 1990 | Etude Epidémiologique auprès de femmes de l’Education Nationale. | French League against Cancer, European Community, 3M Company, Mutuelle Générale de l’Education Nationale, Institut Gustave Roussy, Institut National de la Santé et de la Recherche Médicale, Association pour la Recherche sur le Cancer, Fondation pour la Recherche Médicale | JHL

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
15880532 | Kesse 2005 | Cohort study | France 46° N | 100,000 | Adenoma study: 5320 CRC: 67484 | 52.7 (nd) | nd | 0% | nd | BMI 23.0kg/m ^ 2 ^ | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data ...etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
15880532 | Kesse 2005 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | nd | nd | nd | Vit D (μg) 2.61±1.28 *****
15880532 | Kesse 2005 | Dietary calcium intake | FFQ | Conversion of foods into nutrients was carried out using a French food composition table compiled ad hoc and derived from a major French table the McCance and Widdowson’s food composition table (Ref) | Y, correlation coefficient for dairy products 0.67, for calcium intake 0.38 | | | | | Calcium (mg) 1014.15±359.55 *****

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

***** Cancer-free subjects only

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
15880532 | Kesse 2005 | nd | adenoma | Complete colonoscopy was performed mostly for investigating anemia or bowel symptoms, as well as some times for screening first-degree relatives of subjects with colorectal neoplasia.
15880532 | Kesse 2005 | nd | Colorectal cancer | Mostly diagnosed when symptomatic

UI | Author Year | Comments
15880532 | Kesse 2005 | High risk of adenomas was also included as outcome.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
15880532 | Kesse 2005 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Energy and alcohol intake
15880532 | Kesse 2005 | Demographics (e.g., age, gender, race, education)? | Yes - education
15880532 | Kesse 2005 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes - BMI
15880532 | Kesse 2005 | Medical conditions
15880532 | Kesse 2005 | Medication
15880532 | Kesse 2005 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
15880532 | Kesse 2005 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes - smoking, physical activity level
15880532 | Kesse 2005 | Other | Family hx of colon cancer

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose ***** | No. of Cases (Event) * | No. of Non-cases/Total N ** | Follow up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
15880532 | Kesse 2005 | Colorectal cancer | Ca quartile 1 | | <766.22 | 49 | nd | Median, 82.8 | Adjusted | RR | 1.00 | | | 0.08
| | | Ca quartile 2 | | 766.22–962.63 | 47 | nd | Median, 82.8 | Adjusted | RR | 0.94 | 0.63–1.41
| | | Ca quartile 3 | | 962.63–1201.81 | 39 | nd | Median, 82.8 | Adjusted | RR | 0.78 | 0.51–1.19
| | | Ca quartile 4 | | >1201.81 | 37 | nd | Median, 82.8 | Adjusted | RR | 0.72 | 0.47–1.10

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

***** Quartiles was calculated on the distribution of cancer-free subjects (n=67312)

Subgroup Analyses

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose ***** | No. of Cases (Event) * | No. of Non-cases/Total N ** | Follow up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
15880532 | Kesse 2005 | All adenomas | Ca quartile 1 | | <785.62 | 140 | nd | 44.4 | Adjusted | RR | 1.00 | | | 0.04
| | | Ca quartile 2 | | 785.62–1226.16 | 141 | nd | 44.4 | Adjusted | RR | 0.97 | 0.76–1.22
| | | Ca quartile 3 | | 981.67–1226.16 | 121 | nd | 44.4 | Adjusted | RR | 0.83 | 0.65–1.07
| | | Ca quartile 4 | | >1226.16 | 114 | nd | 44.4 | Adjusted | RR | 0.80 | 0.62–1.03

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

***** Quartiles was calculated on the distribution of polyp-free subjects (n=4804)

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
15880532 | Kesse 2005 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | N | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
15880532 | Kesse 2005 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | N | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
15880532 | Kesse 2005 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Y | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | N | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | No information on exposure assessor blinded to outcome info and outcome assessor blinded to exposure measurement; power calculation not reported; multiple risk factors examined

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Kesse-Guyot 2007

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17536191 | Kesse-Guyot 2007 | RCT-post hoc (cohort follow-up of RCT) | 12741 subjects enrolled in the SU.VI.MAX trial from 1994–1995 and had a follow-up of 8 years. Of these 3836 women had at least 5 24-hourdietary records over the first 18 months | Subjects with a recent cancer event, except for basal cell skin cancers and in situ tumors, during the 5 years preceding the follow-up, subjects with cancers other than breast cancer | 1994–1995 | SU.VI.MAX trial | Gov | GR

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
17536191 | Kesse-Guyot 2007 | RCT-post hoc (cohort follow-up of RCT) | France 46° N | 3836 | 3627 | 51 (6.3) | nd | 0% | nd | BMI: <18.5 = 4.4% 18.5–25 = 75.8% 25.1 – 30.0 = 11.0% >30.0 = 7.7% | Post-menopausal status 52% cases; 41% non-cases 41% Family h/o breast cancer 18.5% cases and controls 9% | Energy adjusted calcium intake 935 mg/d in cases; 994 mg/d in controls

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
17536191 | Kesse-Guyot 2007 | Dietary calcium intake | Computerized questionnaires | nd | nd | | | | | Evaluated were calcium, dairy calcium, and non dairy calcium

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17536191 | Kesse-Guyot 2007 | nd | Incident breast cancer | Self reported and identified through medical record data

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must be explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17536191 | Kesse-Guyot 2007 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Supplement use, saturated fatty acid consumption, vegetable consumption, meat consumption
17536191 | Kesse-Guyot 2007 | Demographics (e.g., age, gender, race, education)? | Yes (education level, marital status and parity)
17536191 | Kesse-Guyot 2007 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes (BMI)
17536191 | Kesse-Guyot 2007 | Medical conditions
17536191 | Kesse-Guyot 2007 | Medication | HRT use
17536191 | Kesse-Guyot 2007 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | Physical activity
17536191 | Kesse-Guyot 2007 | Smoking and other life styles variables | Yes (total alcohol intake, smoking)
17536191 | Kesse-Guyot 2007 | Other | Family hx of breast cancer

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean follow-up | Mean Ca level | No. of Cases (Event) * | Total N ** | Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
17536191 | Kesse-Guyot 2007 | Breast cancer | Q1 | 7.7 y | <807 mg | 32 | 3627 | yes | RR | 1 | | | 0.04
| | | Q2 | 7.7 y | 807–960 mg | 24 | 3627 | yes | RR | 0.73 | (0.42–1.25)
| | | Q3 | 7.7 y | 961–1144 mg | 20 | 3627 | yes | RR | 0.65 | (0.37–1.14)
| | | Q4 | 7.7 y | >1144 mg | 16 | 3627 | yes | RR | 0.50 | (0.27–0.91)
| | Breast cancer in post menopausal women | Q1 | 7.7 y | <807 mg | 14 | nd | yes | RR | 1 | | | 0.64
| | | Q2 | 7.7 y | 807–960 mg | 13 | nd | yes | RR | 0.71 | (0.33–1.54)
| | | Q3 | 7.7 y | 961–1144 mg | 10 | nd | yes | RR | 0.67 | (0.30–1.53)
| | | Q4 | 7.7 y | >1144 mg | 11 | nd | yes | RR | 0.76 | (0.34–1.70)
| | Breast cancer in pre-menopausal women | Q1 | 7.7 y | <807 mg | 18 | nd | yes | RR | 1 | | | 0.01
| | | Q2 | 7.7 y | 807–960 mg | 11 | nd | yes | RR | 0.77 | (0.36–1.66)
| | | Q3 | 7.7 y | 961–1144 mg | 10 | nd | yes | RR | 0.63 | (0.29–1.38)
| | | Q4 | 7.7 y | >1144 mg | 5 | nd | yes | RR | 0.26 | (0.10–0.71)

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
17536191 | Kesse-Guyot | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | N | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | N | a) Level of the exposure in comparative categories(e.g. quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
17536191 | Kesse-Guyot | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | N | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | N | a) Level of the exposure in comparative categories(e.g. quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up<20%? (y/n) | N | b) Analysis was planned when cohort was formed? (y/n) | N
17536191 | Kesse-Guyot | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | N | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Poor reporting of critical elements

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Koh 2006

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17106437 | Koh 2006 | Cohort study | Harvard male undergraduates (1916–1950) who filled out diet questionnaires | baseline cancer or no data on dairy intake | 1960’s | Harvard Alumni Health Study | government | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
17106437 | Koh 2006 | Cohort study | nd | 11014 | 10011 | 67 | nd | 100 | nd | 43% with BMI>25 | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
17106437 | Koh 2006 | Dietary calcium intake | 23 items FFQ (Willett 1985, 1987) | USDA | n | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17106437 | Koh 2006 | primary | prostate cancer | self-reported of physician-diagnosed cancer or death certificates (through 1998)

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17106437 | Koh 2006 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes | red meat intake, vegetable intake
17106437 | Koh 2006 | Demographics (e.g., age, gender, race, education)? | Yes | age
17106437 | Koh 2006 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI
17106437 | Koh 2006 | Medical conditions
17106437 | Koh 2006 | Medication
17106437 | Koh 2006 | Sunlight exposure and its proxy variables (e.g., seasonal variation of25 (OH)D, UV exposure, location)
17106437 | Koh 2006 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | smoking, alcohol, physical activity
17106437 | Koh 2006 | Other | | paternal hx of prostate cancer

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Event * | Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
17106437 | Koh 2006 | prostate cancer | dairy calcium | | 0–199 mg/d | 209 | 10011 | adj | RR | 1.00 (ref) | | | 0.64
| | | | | 200–449 | 167 | 10011 | | | 0.81 | 0.64–1.02
| | | | | 450–599 | 238 | 10011 | | | 0.91 | 0.73–1.14
| | | | | ≥600 | 201 | 10011 | | | 0.91 | 0.70–1.18
17106437 | Koh 2006 | fatal prostate cancer | dairy calcium | | 0–199 mg/d | 30 | 10011 | adj | RR | 1.00 (ref) | | | 0.52
| | | | | 200–449 | 21 | 10011 | | | 0.57 | 0.27–1.19
| | | | | 450–599 | 23 | 10011 | | | 0.60 | 0.29–1.22
| | | | | ≥600 | 25 | 10011 | | | 0.81 | 0.38–1.71

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
17106437 | Koh 2006 | prostate cancer risk | Calcium supplement was not related to risk of prostate cancer (multivariate RR = 1.05 (0.84–1.31). Only 8% of men used supplement (classified as users vs. non-users). Dose not specified.

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
17106437 | Koh 2006 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories(eg quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | N
17106437 | Koh 2006 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories(eg quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
17106437 | Koh 2006 | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | no internal validation of FFQ; retrospective

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Kurahashi 2008

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
18398033 | Kurahashi 2008 | Cohort study | Male Japanese residents age 40–69 at baseline | History of prostate cancer, extreme total energy intake reported | Cohort I launched in 1990, Cohort II launched in 1993 | Japan Public Health Center-Based Prospective Study | Japanese Ministry of Health | KP/SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
18398033 | Kurahashi 2008 | Cohort study | Japan 36°N | 65,801 men in initial cohort | 46,036 | nd | 45–74 | 100% | nd | nd | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
18398033 | Kurahashi 2008 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | NA | NA | NA | NA | NA
| | Dietary calcium intake | FFQ | Standard Tables of Food Composition in Japan, 5 ^ th ^ edition | Yes, correlation coefficient for calcium, comparing FFQ to 14 or 28 day diet records, was 0.43 for cohort I and 0.65 for cohort II | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
18398033 | Kurahashi 2008 | nd | Prostate cancer | Active patient notification from major local hospitals in the study area, linkage with cancer registries, death certificates

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
18398033 | Kurahashi 2008 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Intake of green tea and genistein
18398033 | Kurahashi 2008 | Demographics (e.g., age, gender, race, education)? | Yes | age
18398033 | Kurahashi 2008 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No
18398033 | Kurahashi 2008 | Medical conditions
18398033 | Kurahashi 2008 | Medication
18398033 | Kurahashi 2008 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
18398033 | Kurahashi 2008 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | Smoking status, drinking frequency
18398033 | Kurahashi 2008 | Other | Area, marital status

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
Result | 95% CI | P btw | Result | 95% CI | P btw

* Example: OR Ca/placebo

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | No. of Non-cases/Total N** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups*** | P for trend****
18398033 | Kurahashi 2008 | Prostate cancer | Quartile 1: calcium median = 282.8 mg/d | nd | nd | 56 | nd | Adjusted | RR | 1.00 | Reference | | 0.16
| | | Quartile 2: calcium median = 403.6 mg/d | nd | nd | 68 | nd | | | 1.03 | 0.70–1.51
| | | Quartile 3: calcium median = 521.9 mg/d | nd | nd | 98 | nd | | | 1.32 | 0.92–1.90
| | | Quartile 4: calcium median = 725.1 mg/d | nd | nd | 107 | nd | | | 1.24 | 0.85–1.81

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
18398033 | Kurahashi 2008 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | Y | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories(eg quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders(other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
18398033 | Kurahashi 2008 | b) Sampling of population random or consecutive? (y/n) | NA | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories(eg quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders(other than age and sex)? ** (y/n) | Y | b) Loss to follow-up<20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
18398033 | Kurahashi 2008 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Y | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | N | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Quartiles give medians, not means or ranges; no adjustment for FH of prostate cancer

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence