# Evidence Tables: A-E

## Ahn 2008

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
18505967 | Ahn 2008 | Case-cohort study | Non-Hispanic white males, at least one prostate cancer screen before end of follow-up. All eligible patients with aggressive cancer selected, and a randomly selected subset of those with non-aggressive prostate cancer. | No prior history of prostate cancer before first year of follow-up. | 1993–2001 | Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial (PLCO) | NIH: National Cancer Institute, Intramural Research Program | KP/SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
18505967 | Ahn 2008 | Case-cohort study | United States (various): Birmingham, AL; Denver, CO; Detroit, MI; Honolulu, HI; Marshfield, WI; Minneapolis, MN; Pittsburgh, PA; Salt Lake City, UT; St. Louis, MO; Washington DC | 1530749 cases; 781 controls | 1530 | Case: 67.8 (5.3); Control: 67.6 (5.3) | nd | 100% | Non-Hispanic white | BMI case 27.3 (3.6); BMI control 27.5 (3.9) | No prior history of cancer before randomization | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
18505967 | Ahn 2008 | 25(OH)D | | | | 25(OH)D determined by radioimmunoassay (Heartland Assays) | y, coefficient of variation in subset of 80 patients was 5.9% | nd | nd | nd
18505967 | Ahn 2008 | Dietary calcium intake | FFQ | US Department of Agriculture | n | nd | n | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
18505967 | Ahn 2008 | secondary | Prostate cancer | nd
18505967 | Ahn 2008 | secondary | Aggressive prostate cancer | Gleason sum >=7 or clinical stage III or IV)

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
18505967 | Ahn 2008 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Total calcium intake
18505967 | Ahn 2008 | Demographics (e.g., age, gender, race, education)?
18505967 | Ahn 2008 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI
18505967 | Ahn 2008 | Medical conditions | History of diabetes
18505967 | Ahn 2008 | Medication
18505967 | Ahn 2008 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location)
18505967 | Ahn 2008 | Smoking and other life styles variables | Yes | Vigorous physical activity
18505967 | Ahn 2008 | Other | study center

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥ 2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tirtiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases * | No. of Non- cases | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups *** | P for trend ****
18505967 | Ahn 2008 | prostate cancer | quintiles based on season of collection (standardized) Quintile 1 (12.8–42.5 nmol/L) | nd | nd | 119 | 157 | Adjusted for age at cohort entry; time since screening; calendar year; | OR | 1.00 | (Referent) | | 0.04
| | | Quintile 2 (42.5–51.3 nmol/L) | nd | nd | 125 | 156 | | | 1.12 | 0.79–1.57
| | | Quintile 3 (51.4–60.5 nmol/L) | nd | nd | 190 | 157 | | | 1.61 | 1.16-2.22
| | | Quintile 4 (60.6–71.7 nmol/L) | nd | nd | 167 | 156 | | | 1.42 | 1.02–1.96
| | | Quintile 5 (71.8–129.5 nmol/L) | nd | nd | 148 | 155 | | | 1.32 | 0.94–1.84
18505967 | Ahn 2008 | prostate cancer | quintiles based on season of collection (standardized) Quintile 1 (12.8–42.5 nmol/L) | nd | nd | 119 | 157 | Adjusted for age at cohort entry; time since screening; calendar year; study center; DM; BMI; physical activity; Ca intake | OR | 1.00 | (Referent) | | 0.20
| | | Quintile 2 (42.5–51.3 nmol/L) | nd | nd | 125 | 156 | | | 1.10 | 0.78–1.56
| | | Quintile 3 (51.4–60.5 nmol/L) | nd | nd | 190 | 157 | | | 1.53 | 1.10–2.13
| | | Quintile 4 (60.6–71.7 nmol/L) | nd | nd | 167 | 156 | | | 1.33 | 0.95–1.86
| | | Quintile 5 (71.8–129.5 nmol/L) | nd | nd | 148 | 155 | | | 1.18 | 0.83–1.68
18505967 | Ahn 008 | Aggressive prostate cancer (Gleason sum >=7 or clinical stage III or IV) | Serum 25(OH)D-Quintile 1 (12.8–42.5 nmol/L) | nd | nd | 68 | 157 | Adjusted for age at cohort entry; time since screening; calendar year; study center; DM | OR | 1.00 | (Referent) | nd | 0.05
| | | Quintile 2 (42.5–51.3 nmol/L) | nd | nd | 73 | 156 | | | 1.20 | 0.80–1.81 | nd
| | | Quintile 3 (51.4–60.5 nmol/L) | nd | nd | 130 | 157 | | | 1.96 | 1.34–2.87 | nd
| | | Quintile 4 (60.6–71.7 nmol/L) | nd | nd | 105 | 156 | | | 1.61 | 1.09–2.38 | nd
| | | Quintile 5 (71.8–129.5 nmol/L) | nd | nd | 90 | 155 | | | 1.37 | 0.92–2.05 | nd
| | Aggressive prostate cancer (Gleason sum >=7 or clinical stage III or IV) | Serum 25(OH)D-Quintile 1 (12.8–42.5 nmol/L) | nd | nd | 68 | 157 | Adjusted for age at cohort entry; time since screening; calendar year; study center; DM; BMI; physical activity; Ca intake | OR | 1.00 | (Referent) | | 0.09
| | | Quintile 2 (42.5–51.3 nmol/L) | nd | nd | 73 | 156 | | | 1.18 | 0.78–1.79
| | | Quintile 3 (51.4–60.5 nmol/L) | nd | nd | 130 | 157 | | | 1.92 | 1.31–2.82
| | | Quintile 4 (60.6–71.7 nmol/L) | nd | nd | 105 | 156 | | | 1.56 | 1.05–2.31
| | | Quintile 5 (71.8–129.5 nmol/L) | nd | nd | 90 | 155 | | | 1.34 | 0.87–1.98

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = − 6; group 1 vs. 2 = − 8

**** P value for testing the linear trend of the OR/RR across different categories or doses

MEAN DATA

THIS SHOULD ONLY APPLY TO CASE-COHORT STUDIES THAT COMPARE BASELINE VIT D/CA LEVELS BETWEEN CASES (WITH DISEASE) AND CONTROLS (WITHOUT DISEASE)

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Mean 25(OH)D Level | Vit D level CI/SE/SD* | Mean Ca intake or Ca balance | Ca CI/SE/SD* | P between groups
18505967 | Ahn 2008 | Prostate cancer cases: | 2–8 years | crude | 749 | 59.0 | 19.1 | nd | nd | 25(OH)D: 0.18
18505967 | Ahn 2008 | Prostate cancer controls: | 2–8 years | crude | 781 | 57.6 | 18.9 | nd | nd

Duplicate one table per outcome

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
18505967 | Ahn 2008 | a) Eligibility criteria clear? (y/n) | y | a) Exposure assessor blinded to outcome info? (y/n) | y | a) Method reported? (y/n) | y | a) One of the prespecified methods was used? (y/n) | y | a) Level of the exposure in comparative categories (eg quartiles) y is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | a) Clear definition of outcome, including time of ascertainment? (y/n) | y | a) Prospective collection of data? (y/n) | y
18505967 | Ahn 2008 | b) Sampling of population random or consecutive? (y/n) | nd | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | y | Time from sample collection to sample analysis reported? (y/n) | y | a) Level of the exposure in comparative categories (eg quartiles) y is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | b) Loss to follow-up <20%? (y/n) | y | b) Analysis was planned when cohort was formed? (y/n) | nd
18505967 | Ahn 2008 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | n | | | | | b) Justification of final adjusted model selection? (y/n) | y | c) Do the authors specify a primary outcome? (y/n) | n | c) Justification of sample size (includes sample size calculations)? (y/n) | n
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | While all cases of aggressive cancers were selected; only a randomly picked subset of nonaggressive cancers were selected.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

## Ahonen 2000

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
11075874 | Ahonen 2000 | Case-cohort study | Employees in two Finnish governmental agencies and five industrial companies | Previously clinically detected prostate cancer | 1981–1982 | Helsinki Heart Study | Finnish Cancer Foundation, Yrjo Jahnsson Foundation, Medical Research Fund of Tampere University Hospital, Tampere University | KP/SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location(e.g., City and Country, latitude) | N enrolled | N analyzed | Mean(SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data(e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake…etc.)
11075874 | Ahonen 2000 | Case-cohort study | Finland 62°(various cities) | 715 cases: 149 control: 566 | 715 | nd | 40–57 | 100% | nd | nd | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
11075874 | Ahonen 2000 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | Radioimmunoassay (Incstar Corporation) | Intra-assay coefficient of variation = 8.5%, Inter-assay coefficient of variation = 16% | Same day | Jan-Feb; March-May; September | nd
| | Dietary calcium intake | nd | nd | nd | nd | nd | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
11075874 | Ahonen 2000 | Nd | Prostate cancer | nd

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
11075874 | Ahonen 2000 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
11075874 | Ahonen 2000 | Demographics (e.g., age, gender, race, education)? | Yes | Age (matched), residence (matched)
11075874 | Ahonen 2000 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI
11075874 | Ahonen 2000 | Medical conditions | Systolic blood pressure, HDL
11075874 | Ahonen 2000 | Medication | Treatment with gemfibrozil
11075874 | Ahonen 2000 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | Yes | time of sample retrieval
11075874 | Ahonen 2000 | Smoking and other life styles variables | Yes | Smoking
11075874 | Ahonen 2000 | Other | Time of sample retrieval (matched)

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tirtiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases * | No. of Non-cases | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups *** | P for trend ****
11075874 | Ahonen 2000 | Prostate cancer | Quartile cut off based on total original cohort; Quartile 4: 25(OH)D > 55 nmol/L | nd | nd | 34 | 144 | crude | OR | 1 | | | 0.01
| | | Quartile 3: 25(OH)D = 41–54 nmol/L | nd | nd | 26 | 148 | crude | OR | 0.8 | 0.4–1.4
| | | Quartile 2: 25(OH)D = 31–40 nmol/L | nd | nd | 41 | 143 | crude | OR | 1.3 | 0.8–2.3
| | | Quartile 1: 25(OH)D = < 30 nmol/L | nd | nd | 48 | 131 | crude | OR | 1.7 | 1.0–3.0
11075874 | Ahonen 2000 | Prostate cancer | Quartile cut off based on total original cohort; Quartile 4: 25(OH)D > 55 nmol/L | nd | nd | 34 | 144 | adjusted for HDL; SBP; BMI | OR | 1 | | | 0.01
| | | Quartile 3: 25(OH)D = 41–54 nmol/L | nd | nd | 26 | 148 | Adjusted | OR | 0.8 | 0.5–1.5 | nd
| | | Quartile 2: 25(OH)D = 31–40 nmol/L | nd | nd | 41 | 143 | Adjusted | OR | 1.4 | 0.8–2.4 | Nd
| | | Quartile 1: 25(OH)D = < 30 nmol/L | nd | nd | 48 | 131 | Adjusted | OR | 1.8 | 1.0–3.2 | nd
| | Prostate cancer in those <52 years old at entry | Group 1: 25(OH)D >40 | nd | nd | nd | nd | adjusted HDL; SBP; BMI | OR | 1
| | | Group 2: 25(OH)D≤40 | nd | nd | nd | nd | adjusted | OR | 3.5 | 1.7–7.0 | Group 2 vs. 1 = 0.0006
| | Prostate cancer in those >51 years old at entry | Group 1: 25(OH)D >40 | nd | nd | nd | nd | Adjusted | OR | 1
| | | Group 2: 25(OH)D≤40 | nd | nd | nd | nd | adjusted | OR | 1.2 | 0.7–2.1 | Group 2 vs. 1 = NS

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
11075874 | Ahonen 2000 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | Y | a) Method reported? (y/n) | na | a) One of the prespecified methods was used? (y/n) | y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | a) Clear definition of outcome, including time of ascertainment? (y/n) | n | a) Prospective collection of data? (y/n) | y
11075874 | Ahonen 2000 | b) Sampling of population random or consecutive? (y/n) | NA | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | na | Time from sample collection to sample analysis reported? (y/n) | n | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | b) Loss to follow-up <20%? (y/n) | na | b) Analysis was planned when cohort was formed? (y/n) | nd
11075874 | Ahonen 2000 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | na | | | | | b) Justification of final adjusted model selection? (y/n) | y | c) Do the authors specify a primary outcome? (y/n) | n | c) Justification of sample size (includes sample size calculations)? (y/n) | n
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | details of prostate cancer diagnosis not reported; 39% of the stored samples were thawed; no adjustment for additional factors relevant to prostate cancer

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

## Al-Delaimy 2003

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
12663277 | Al-Delaimy 2003 | Cohort Study | Men, 40–75 y, health professional | Kcal intake outside 800–4200 kcal/day, ≥70 items omitted on FFQ Nonmelanoma cancer before IHD, CVD at baseline. | 1986 | Health Professionals Follow-up Study | Gov’t | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
12663277 | Al- Delaimy 2003 | Cohort Study | US, various | 39,800 | 39,800 (415,965 person years) | ~54 (~9) | 40–75 | 100% | White close to 100% | ~25.5 ± ~3.4 | Healthy | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
12663277 | Al- Delaimy 2003 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | nd | nd | nd | nd
| | Dietary calcium intake | FFQ | USDA, release 10, 1995 + other sources | Yes Random sample of 127 men in Boston. FFQ compared to diet record. Correlation coefficient = 0.64 | | | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
12663277 | Al-Delaimy 2003 | 1° | Fatal ischemic heart disease | Including sudden death. Death various sources, confirmed by medical records, autopsy, death certificate.
| | 1° | Nonfatal MI | Self-reporting with medical record confirmation (WHO criteria)
| | 2° | Total ischemic heart disease | Implied combination of fatal IHD and nonfatal MI

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
12663277 | Al-Delaimy 2003 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes | Energy intake
12663277 | Al-Delaimy 2003 | Demographics (e.g., age, gender, race, education)? | Yes | Age
12663277 | Al-Delaimy 2003 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI
12663277 | Al-Delaimy 2003 | Medical conditions | Yes | DM, Hypercholesterolemia
12663277 | Al-Delaimy 2003 | Medication | Yes | Aspirin, Vitamin E
12663277 | Al-Delaimy 2003 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
12663277 | Al-Delaimy 2003 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | Smoking, EtOH, Physical activity
12663277 | Al-Delaimy 2003 | Other | Yes | Family Hx of MI

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥ 2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non-cases/Total N ** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups *** | P for trend ****
12663277 | Al- Delaimy 2003 | IHD (fatal + nonfatal) | Total calcium Quintile 1 | | 523 | 300 | 7960 | 12 years | Adjusted (“multivariate”) | RR | 1.0 | -- | | 0.43
| | | Quintile 2 | | 670 | 296 | 7960 | | | | 1.03 | 0.88, 1.22
| | | Quintile 3 | | 803 | 267 | 7960 | | | | 0.92 | 0.78, 1.09
| | | Quintile 4 | | 995 | 299 | 7960 | | | | 1.01 | 0.85, 1.19
| | | Quintile 5 | | 1377 | 296 | 7960 | | | | 0.94 | 0.79, 1.11
12663277 | Al- Delaimy 2003 | Nonfatal MI | Total calcium Quintile 1 | | 523 | 212 | 7960 | 12 years | Adjusted (“multivariate”) | RR | 1.0 | -- | | 0.43
| | | Quintile 2 | | 670 | 206 | 7960 | | | | 1.01 | 0.83, 1.23
| | | Quintile 3 | | 803 | 197 | 7960 | | | | 0.96 | 0.78, 1.17
| | | Quintile 4 | | 995 | 220 | 7960 | | | | 1.04 | 0.85, 1.28
| | | Quintile 5 | | 1377 | 195 | 7960 | | | | 0.92 | 0.74, 1.14
12663277 | Al- Delaimy 2003 | Fatal IHD | Total calcium Quintile 1 | | 523 | 88 | 7960 | 12 years | Adjusted (“multivariate”) | RR | 1.0 | -- | | 0.72
| | | Quintile 2 | | 670 | 90 | 7960 | | | | 1.17 | 0.87, 1.50
| | | Quintile 3 | | 803 | 70 | 7960 | | | | 0.93 | 0.67, 1.29
| | | Quintile 4 | | 995 | 79 | 7960 | | | | 1.06 | 0.77, 1.47
| | | Quintile 5 | | 1377 | 101 | 7960 | | | | 1.10 | 0.79, 1.51

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
12663277 | Al-Delaimy 2003 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | nd | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
| | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | Y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | ?
| | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Y | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | A
Explanation for Overall Quality Grade (if not Grade A): . | | | | | | | No flaws. Well analyzed.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Aloia 1995

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
7892882 | Aloia 1995 | RCT | Healthy white women between 6 months and 6 years after a natural menopause. | Nd | nd | nd | NIH | KP

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
7892882 | Aloia 1995 | RCT | Mineola, NY, USA, 40° | 118 | 64 (+30 in HRT arm) | -Calcium group: 52(0.6) yrs -Placebo group: 53.4(0.6) yrs | nd | 0% | White 100% | -Weight: calcium group 65.8 (1.5) kg; placebo group 65.6 (1.8) kg -BMI: calcium group 24.6(0.5); placebo group 24.7(0.6) | Nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
7892882 | Aloia 1995 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | nd | nd | nd | Nd
| | Dietary calcium intake | Nd | nd | nd | nd | nd | | nd | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
7892882 | Aloia 1995 | Calcium supplement | nd about type | 1700 mg Ca | 2.9 +/− 1.1 yrs. | nd
| | Calcium placebo | | | | Nd
Co-intervention(s) * : | | | 400 IU vitamin D in all groups
Compliance/Adherence: | | | nd

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
7892882 | Aloia 1995 | 2° | Body weight | Change in kg/yr

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
7892882 | Aloia 1995 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
7892882 | Aloia 1995 | Demographics (e.g., age, gender, race, education)? | No
7892882 | Aloia 1995 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No
7892882 | Aloia 1995 | Medical conditions
7892882 | Aloia 1995 | Medication
7892882 | Aloia 1995 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
7892882 | Aloia 1995 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | No
7892882 | Aloia 1995 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline CI/SE/SD * | Final or Delta ** | Final or Delta CI/SE/SD * | Net difference | Net difference CI/SE/SD * | P between
7892882 | Aloia 1995 | Body weight | kg | Calcium | 2.9 yrs | 36 | 65.8 | SD = 1.5 | Delta = +0.1 | Nd | 0.0 | ND | Not significant
7892882 | Aloia 1995 | Body weight | kg | placebo | 2.9 yrs | 28 | 65.6 | SD = 1.8 | Delta = +0.1 | nd

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or − 2.8

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
7892882 | Aloia 1995 | RCT-parallel | Y | ND | nd | No | nd | nd | y | n | y | C
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | High dropout rate. Inadequate reporting of outcomes of interest.

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Alonso 2005

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
16280427 | Alonso 2005 | Cohort Study | University graduates or registered nurses | History of CVD, cancer, DM, prevalent HTN, extreme total energy intakes (<400 or >3500 women; <600 or >4200 men), missing data | 12/99-1/2002 | U Navarra Follow-up Study | Govt, University | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location(e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake…etc.)
16280427 | Alonso 2005 | Cohort Study | Navarra Spain, 42° 40′ | ~7470 (incl missing data) | 6686 | 36 (~11) | 20–90 | 39% | nd (educated Spaniards) | BMI 23.1 | No HTN | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
16280427 | Alonso 2005 | Dietary calcium intake | FFQ | Spanish food composition tables (referenced) | (Previously validated in Spain) | NA | NA | | NA | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
16280427 | Alonso 2005 | 1° | HTN, incident | Physician diagnosis (self-reported)

UI | Author Year | Comments
16280427 | Alonso 2005 | In a validation study of 127 participants, with a HTN threshold of 160/95, negative predictive value of self-reported = 98%; with threshold of 140/90, NPV = 85% and PPV=82%

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
16280427 | Alonso 2005 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes | Na consumption, total energy consumption
16280427 | Alonso 2005 | Demographics (e.g., age, gender, race, education)? | Yes | Age, Sex
16280427 | Alonso 2005 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI
16280427 | Alonso 2005 | Medical conditions | Yes | Hypercholesterolemia
16280427 | Alonso 2005 | Medication
16280427 | Alonso 2005 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
16280427 | Alonso 2005 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | Physical activity, EtOH, smoking
16280427 | Alonso 2005 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Follow- up | Mean Ca level/dose | No. of Cases (Event)* | Person Years (N) | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups*** | P for trend****
16280427 | Alonso 2005 | HTN | Quintile 1 | 2 y | nd (mean 0.9±0.2) * | 39 (14.3/1000 p-yr) | 2734 p- yr (~1337) | Adjusted | HR | 1 | -- | | 0.67
| | | Quintile 2 | | nd (mean 1.0±0.2) * | 39 (14.3/1000 p-y | 2726 p- yr (~1337) | | | 0.98 | 0.62, 1.54 | NS
| | | Quintile 3 | | nd (mean 1.2±0.2) * | 35 (12.9/1000 p-y | 2706 p- yr (~1337) | | | 0.82 | 0.51, 1.30 | NS
| | | Quintile 4 | | nd (mean 1.4±0.3) * | 30 (11.2/1000 p-y | 2668 p- yr (~1337) | | | 0.73 | 0.45, 1.19 | NS
| | | Quintile 5 | | nd (mean 1.7±0.4) * | 37 (13.7/1000 p-y | 2692 p- yr (~1337) | | | 0.97 | 0.61, 1.54 | NS

UI | Author Year | Comments for Results
| | Quintiles are for total dairy consumption, not calcium.

* Mean±SD calcium intake within quintile of total dairy consumption

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
16280427 | Alonso 2005 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | nd | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | N | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Yes | a) Clear definition of outcome, including time of ascertainment? (y/n) | Yes | a) Prospective collection of data? (y/n) | Yes
16280427 | Alonso 2005 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | Y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | N | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Yes | b) Loss to follow-up <20%? (y/n) | Yes | b) Analysis was planned when cohort was formed? (y/n) | Yes
16280427 | Alonso 2005 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | No | c) Do the authors specify a primary outcome? (y/n) | Yes | c) Justification of sample size (includes sample size calculations)? (y/n) | No
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | No data on range of Ca intake within quintiles

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Andersen 2008

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
18208636 | Andersen, 2008 | RCT | General Pakistani immigrants primarily living in the Copenhagen area Denmark (latitude 55 N°), recruited through various information meetings, radio and television, and posters. | Medications known to affect bone metabolism or serum 25(OH)D concentrations, serious illness, pregnancy, planning pregnancy within 1 yr, breastfeeding, and serum ionized Ca concentrations >1.5 mmol/L. Subjects with Incomplete data in one or more of the explanatory variables were excluded from the analyses. | Jan 2002 to Nov 2002 | nd | nd | Mc

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc.) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
18208636 | Andersen, 2008 | RCT | Copenhagen area, Denmark (55 N°) | 199 | 147 | Median age - Adolescent girls: 12.2 Women: 36.2 Men: 38.3 | Range– Adolescent girls: 10.1–14.7 Women: 18.1–52.7 Men: 17.9–63.5 | 42 | Pakistani | Median BMI - Adolescent girls: 19.5 Women: 27 Men: 26.7 | Generally healthy | No hypercalcimia

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed information as possible on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
18208636 | Andersen, 2008 | 25(OH)D | | | | HPLC using a diode array detector | Yes Interassay CV=6.3% and intraassy CV=4.3% | nd | All seasons (blood were drawn three time, baseline, 6 mo and 1 yr) | See baseline variables
| | Dietary calcium intake | FFQ | General Intake Estimation System described elsewhere | no | no | | | | Median Ca intake (mg/d) - Adolescent girls: 510 Women: 495 Men: 548

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
18208636 | Andersen, 2008 | Vitamin D3 | Scanphrm A/S (Birkerod, Denmark) | 10 ug/d | 1 yr | Daily
| | Vitamin D3 | | 20 ug/d | 1 yr | Daily
| | placebo | Cellulosum microcristallium | 0 | 1 yr | Daily
Co-intervention(s) * : | | | none
Compliance/Adherence: | | | Tablet counting. The median compliance was 85 (range 43–100), 92 (42–115) and 93 (33–105)% for girls, women, and men, respectively

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
18208636 | Andersen, 2008 | primary | 25(OH)D
| | primary | BMD, BMC | DXA, whole body, or lumbar spine

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
18208636 | Andersen, 2008 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
18208636 | Andersen, 2008 | Demographics (e.g., age, gender, race, education)? | Yes * | age
18208636 | Andersen, 2008 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes/no *
18208636 | Andersen, 2008 | Medical conditions
18208636 | Andersen, 2008 | Medication
18208636 | Andersen, 2008 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
18208636 | Andersen, 2008 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes/no *
18208636 | Andersen, 2008 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure Category/Intervention Group | Crude or Adjusted analysis? | Mean Follow-up (months) | No. Analyzed **** | Baseline | Baseline IQR | Final ** | Final IQR * | Net difference *** | Net difference CI/SE/SD * | P between groups ***
18208636 | Andersen, 2008 | 25(OH)D | nmol/L | Girls - Placebo | crude | 12 | 8/7 | 7.3 | 5.3, 23.6 | 5.75 | 4.88, 16.0 | nd | nd | Ref
| | | | Girls - Vit D3 10 ug/d | | | 9/7 | 16.9 | 12.1, 21.1 | 47.0 | 28.7, 61.5 | | | 0.03
| | | | Girls - Vit D320 ug/d | | | 9/7 | 8.8 | 5.2, 17.1 | 29.3 | 28.5, 64.0 | | | NS
18208636 | Andersen, 2008 | 25(OH)D | nmol/L | Women - Placebo | crude | 12 | 29/19 | 11.7 | 7.5, 19.4 | 10.1 | 8.38, 16.1 | nd | nd | Ref
| | | | Women - Vit D3 10 ug/d | | | 30/21 | 9.95 | 6.9, 14.3 | 40.9 | 37.4, 47.7 | | | <0.0001
| | | | Women - Vit D3 20 ug/d | | | 30/22 | 14.0 | 8.3, 17.5 | 46.2 | 38.6, 53.2 | | | <0.0001
18208636 | Andersen, 2008 | 25(OH)D | nmol/L | Men - Placebo | crude | 12 | 27/20 | 20 | 15, 25.2 | 19.1 | 13.1, 22.6 | nd | nd | Ref
| | | | Men - Vit D310 ug/d | | | 26/19 | 22.9 | 12.6, 28.2 | 39.4 | 31, 48.2 | | | <0.0001
| | | | Men - Vit D320 ug/d | | | 31/26 | 18.9 | 13.6, 29.2 | 54.7 | 45.2, 65.1 | | | <0.0001
18208636 | Andersen, 2008 | BMC– whole body | G | Girls - Placebo | crude | 12 | 8/7 | 1666 | 1399, 1767 | 1923 | 1730, 2145 | nd | nd | Ref
| | | | Girls - Vit D310 ug/d | | | 9/7 | 1308 | 1104, 1726 | 1595 | 1302, 1953 | | | NS
| | | | Girls - Vit D320 ug/d | | | 9/7 | 1473 | 1209, 1887 | 1625 | 1380, 21440 | | | NS
18208636 | Andersen, 2008 | BMD–lumbar spine | g/cm2 | Women - Placebo | crude | 12 | 29/18 | 0.99 | 0.91, 1.12 | 1.00 | 0.89, 1.16 | nd | nd | Ref
| | | | Women - Vit D3 10 ug/d | | | 30/21 | 1.06 | 0.99, 1.06 | 1.06 | 1.01, 1.11 | | | NS
| | | | Women - Vit D3 20 ug/d | | | 30/21 | 0.98 | 0.93, 1.05 | 0.99 | 0.93, 1.06 | | | NS
18208636 | Andersen, 2008 | BMD– lumbar spine | g/cm2 | Men - Placebo | crude | 12 | 27/19 | 1.03 | 0.96, 1.14 | 1.06 | 0.90, 1.14 | nd | nd | Ref
| | | | Men - Vit D310 ug/d | | | 25/19 | 1.03 | 0.94, 1.07 | 1.05 | 0.97, 1.11 | | | NS
| | | | Men - Vit D320 ug/d | | | 31/26 | 0.92 | 0.89, 1.08 | 1.00 | 0.88, 1.12 | | | NS

Duplicate one row per exposure category or intervention group. Please write “nd” if there was no data reported. DO NOT LEAVE BLANK.

* Please choose one and delete the others

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** Baseline/follow-up n

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
18208636 | Andersen, 2008 | RCT | nd | nd | NA | no | nd | yes | yes | no | yes | B
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Very small size for girls (therefore downgraded to C). Dropout rates were different between treatment groups. Compliance was lower for girls. Blinding was not described.

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse events.

## Armas 2004

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
15531486 | Armas 2004 | RCT | men in good health; <16 oz milk qd; <10 h sun exposure per wk | granulomatous conditions; liver, kidney disease; DM; on anticonvulsants, barbiturates or steroids | 2003 | - | academic | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
15531486 | Armas 2004 | RCT | Omaha, NE (41.2º) | 30 | 30 | 33 (11.5) | 20–61 | 100 | nd | BMi 27.1 | good health | 4 subjects took multivitamin averaging 1 time per wk before enrollment

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
15531486 | Armas 2004 | 25(OH)D | | | | RIA (IDS & DiaSorin) | n | nd | July | nd
| | Dietary calcium intake

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
15531486 | Armas 2004 | vit D2 | Sidmark Lab., NC | 50000 IU | 1 time only | one tablet
| | vit D3 | Tishcon Corp., NC | 50000 IU | 1 time | 10 tablets of 5000 IU each
| | no supplement, seasonal effect only
Co-intervention(s) * :
Compliance/Adherence: | | | 100%

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
15531486 | Armas 2004 | primary | change in 25(OH)D | sum of 25(OH)D2 and 25(OH)D3
| | | (AUC) for 25 (OH)D

UI | Author Year | Comments
15531486 | Armas 2004 | 4 subjects took multivitamin averaging 1 time per wk, stopped 1 wk before and throughout the study; control 25 (OH)D level used to adjust for sunlight exposure in the active intervention subjects

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
15531486 | Armas 2004 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
15531486 | Armas 2004 | Demographics (e.g., age, gender, race, education)? | no *
15531486 | Armas 2004 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no *
15531486 | Armas 2004 | Medical conditions
15531486 | Armas 2004 | Medication
15531486 | Armas 2004 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | yes | sunlight exposure
15531486 | Armas 2004 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no *
15531486 | Armas 2004 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline CI/SE/SD * | Delta ** or Final | Final or Delta CI/SE/SD * | Net difference | Net difference CI/SE/SD * | P between
15531486 | Armas 2004 | change in 25(OH)D | nmol/L | vit D2 | 7d | 10 | 0 *** | | 8 ***
15531486 | Armas 2004 | change in 25(OH)D | nmol/L | vit D3 | 7d | 10 | 0 *** | | 15 ***
| | | | vit D2 | 14d | 10 | 0 *** | | 2 ***
| | | | vit D3 | 14d | 10 | 0 *** | | 17 ***
| | | | vit D2 | 28d | 10 | 0 *** | | −5 ***
| | | | vit D3 | 28d | 10 | 0 *** | | 12 ***
| | Area under the curve (AUC) for 25 (OH)D | nmol.d/L | vit D2 | 28d | 10 | | | 150.5 | 58.5 | | | <0.002
| | Area under the curve (AUC) for 25 (OH)D | nmol.d/L | vit D3 | 28d | 10 | | | 511.8 | 80.9

*** adjusted for seasonal risk in 25(OH)D; all values estimated from Figure 2 in paper

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “− “ sign: e.g. +2.8 or −2.8

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
15531486 | Armas 2004 | RCT | nd | nd | nd | y | n | n | n | n | y | C
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | unclear how the subjects were chosen; relatively small number of subjects; incomplete reporting of analysis; did not adjust for all potentially relevant variables

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Ascherio 1992

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
1330360 | Ascherio 1992 | Cohort study | Male health professionals, 40–75 y | Caloric intake <800 or>4200 kcal/d, incomplete FFQ, nonmelanoma cancer, CVD, diabetes, kidney failure, high cholesterol, digoxin, nitrates, antihypertensive medications | 1986 | Health Professionals Follow-up Study | NIH | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
1330360 | Ascherio 1992 | Cohort study | US, various | 30,681 | 30,681 | Median ~50 | 40–75 | 100 | White close to 100% | nd | Healthy | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
1330360 | Ascherio 1992 | Dietary calcium intake | FFQ | nd | Yes Ca correlation 0.53 | NA | NA | | NA | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
1330360 | Ascherio 1992 | 1° | Incident HTN | self-reported diagnosis (collected BP data, but apparently didn’t use) Validated

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
1330360 | Ascherio 1992 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
1330360 | Ascherio 1992 | Demographics (e.g., age, gender, race, education)? | Yes | Age
1330360 | Ascherio 1992 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI
1330360 | Ascherio 1992 | Medical conditions
1330360 | Ascherio 1992 | Medication
1330360 | Ascherio 1992 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
1330360 | Ascherio 1992 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | EtOH
1330360 | Ascherio 1992 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Ca intake | No. of Cases(Event) * | Total N ** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric(e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups *** | P for trend ****
1330360 | Ascherio 1992 | Incident HTN | Ca intake Categories | | <500 | 85 | 1677 | 4 y | Adjusted | RR | 1.17 | 0.91, 1.50 | NS | 0.53
| | | | | 500–699 | 297 | 7504 | | | | 0.91 | 0.77, 1.07 | NS
| | | | | 700–899 | 333 | 8576 | | | | 0.89 | 0.76, 1.04 | NS
| | | | | 900–1099 | 195 | 5038 | | | | 0.91 | 0.76, 1.09 | NS
| | | | | ≥1100 | 338 | 7890 | | | | 1.00 | -- | --

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

≥ 2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | | Ca intake | No. of Cases(Event)* | Total N** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric(e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups*** | P for trend****
1330360 | Ascherio 1992 | Incident HTN | Ca intake Categories | Age≤50 | <500 | nd | 14354 | 4 y | Adjusted | RR | 1.52 | nd | <.05 | nd
| | | | | 500–1099 | nd | 14354 | | | | 0.86 | nd | NS
| | | | | ≥1100 | nd | 14354 | | | | 1.00 | -- | --
| | | | Age>50 | <500 | nd | 16314 | | | | 0.98 | nd | NS | nd
| | | | | 500–1099 | nd | 16314 | | | | 0.91 | nd | NS
| | | | | ≥1100 | nd | 16314 | | | | 1.00 | -- | --

Duplicate one row per exposure category or intervention group.

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
1330360 | Ascherio 1992 | a) Eligibility criteria clear? (y/n) | Yes | a) Exposure assessor blinded to outcome info? (y/n) | nd | a) Method reported? (y/n) | Yes | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories(eg quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | Yes | a) Adjusted or matched for ANY confounders(other than age and sex)? ** (y/n) | Yes | a) Clear definition of outcome, including time of ascertainment? (y/n) | Probably | a) Prospective collection of data? (y/n) | Yes
1330360 | Ascherio 1992 | b) Sampling of population random or consecutive? (y/n) | Yes | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | No | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories(eg quartiles) is given(ranges)? (y/n) applicable for categorical analyses only | Yes | a) Adjusted or matched for ANY confounders(other than age and sex)? ** (y/n) | Yes | b) Loss to follow-up<20%? (y/n) | Yes | b) Analysis was planned when cohort was formed? (y/n) | Yes
1330360 | Ascherio 1992 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Yes | | | | | b) Justification of final adjusted model selection? (y/n) | No | c) Do the authors specify a primary outcome? (y/n) | Yes | c) Justification of sample size (includes sample size calculations)? (y/n) | No
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Definition of HTN not clear (self reported, probably didn’t use BP threshold, probably should have if not)

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Ascherio 1996

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
8621198 | Ascherio 1996 | Cohort study | Female nurses, 30–55 y, completed FFQ | HTN, CVD, DM, nonmelanoma cancer, antihypertensive drug, on special diet, recent pregnancy prior to FFQ | 1976 | Nurses’ Health Study | NIH | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data(e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
8621198 | Ascherio 1996 | Cohort study | US, various | 59,670 | 41,541 | nd | 30–55 | 0 | White 98% | nd | Healthy | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
8621198 | Ascherio 1996 | Dietary calcium intake | FFQ | USDA + other sources | Yes correlation Ca 0.62 | NA | NA | | NA | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
8621198 | Ascherio 1996 | 1° | Incident HTN | Self-reported; apparently did not use BP threshold Validated

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
8621198 | Ascherio 1996 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
8621198 | Ascherio 1996 | Demographics (e.g., age, gender, race, education)? | Yes | Age
8621198 | Ascherio 1996 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI
8621198 | Ascherio 1996 | Medical conditions
8621198 | Ascherio 1996 | Medication
8621198 | Ascherio 1996 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
8621198 | Ascherio 1996 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | EtOH
8621198 | Ascherio 1996 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Ca intake | No. of Cases (Event) * | Person years | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups *** | P for trend ****
8621198 | Ascherio 1996 | Hypertension | Ca intake category 1 | | <400 | 87 | 5,581 | 14 y | Adjusted | RR | 1.0 | -- | -- | 0.76
| | | category 2 | | 400-599 | 608 | 36,605 | | | | 1.07 | 0.85, 1.35 | NS
| | | category 3 | | 600-799 | 712 | 42,544 | | | | 1.05 | 0.83, 1.31 | NS
| | | category 4 | | 800-1000 | 407 | 24,240 | | | | 1.03 | 0.82, 1.31 | NS
| | | category 5 | | ≥1000 | 712 | 41,325 | | | | 1.04 | 0.83, 1.31 | NS

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
8621198 | Ascherio 1996 | a) Eligibility criteria clear? (y/n) | Yes | a) Exposure assessor blinded to outcome info? (y/n) | nd | a) Method reported? (y/n) | Yes | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Yes | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Yes | a) Clear definition of outcome, including time of ascertainment? (y/n) | Yes | a) Prospective collection of data? (y/n) | Yes
8621198 | Ascherio 1996 | b) Sampling of population random or consecutive? (y/n) | Yes | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | Yes | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Yes | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Yes | b) Loss to follow-up <20%? (y/n) | Probably | b) Analysis was planned when cohort was formed? (y/n) | ?
8621198 | Ascherio 1996 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Yes | | | | | b) Justification of final adjusted model selection? (y/n) | Yes | c) Do the authors specify a primary outcome? (y/n) | Yes | c) Justification of sample size (includes sample size calculations)? (y/n) | No
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Probably incomplete definition of incident HTN (BP not used)

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Ascherio 1998

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
9743511 | Ascherio 1998 | Cohort study | Male health professionals, 40–75 y | Calorie intake <800 or >4200/day, incomplete FFQ, CVD, DM | 1986 | Health Professionals Follow-up Study | Gov’t | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake etc.)
9743511 | Ascherio 1998 | Cohort study | US, various | 43,738 | 43,738 (implied) | nd | 40–75 | 100 | mostly White | nd | Healthy | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
9743511 | Ascherio 1998 | Dietary calcium intake | FFQ | nd | Yes Correlation Ca 0.53 | NA | NA | | NA | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
9743511 | Ascherio 1998 | 1° | Incident stroke | Fatal or nonfatal stroke by report, confirmed by medical records with standard definitions, excluding infection or neoplasia caused strokes
| | | specific stroke types | not extracted

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
9743511 | Ascherio 1998 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes | Total energy intake
9743511 | Ascherio 1998 | Demographics (e.g., age, gender, race, education)? | Yes | Age
9743511 | Ascherio 1998 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI
9743511 | Ascherio 1998 | Medical conditions | Yes | HTN, hypercholesterolemia
9743511 | Ascherio 1998 | Medication
9743511 | Ascherio 1998 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
9743511 | Ascherio 1998 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | Smoking, EtOH, physical activity
9743511 | Ascherio 1998 | Other | | Parental early MI, profession

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Median Ca intake | No. of Cases (Event) * | Total N (person years) | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups *** | P for trend ****
9743511 | Ascherio 1998 | Stroke | Calcium intake Quintile 1 | | 500 | 75 | ~8748 (64,728) | 8 y | Adjusted “multivariate” | RR | 1.0 | -- | -- | 0.10
| | | Quintile 2 | | 700 | 69 | ~8748 (65,534) | | | | 0.95 | 0.68, 1.32 | NS
| | | Quintile 3 | | 800 | 51 | ~8748 (64,596) | | | | 0.72 | 0.50, 1.03 | NS
| | | Quintile 4 | | 1000 | 63 | ~8748 (64,425) | | | | 0.84 | 0.60, 1.19 | NS
| | | Quintile 5 | | 1400 | 70 | ~8748 (64,112) | | | | 0.88 | 0.63, 1.23 | NS

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
9743511 | Ascherio 1998 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | implied | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is Only given median (ranges)? (y/n) applicable for categorical analyses only | Only median | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection data? (y/n)
9743511 | Ascherio 1998 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | Y | b) Food composition database or suppl composition reported? (y/n) | No (in other papers though) | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is Only given median (ranges)? (y/n) applicable for categorical analyses only | Only median | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Probably | b) Analysis was planned when cohort was formed (y/n)
9743511 | Ascherio 1998 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Y | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includessample calculations)?(y/n)
OVERALL Grade (A/B/C): | | | | | | | A
Explanation for Overall Quality Grade (if not Grade A):

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Baron 2005

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
15767334 | Baron 2005 | RCT-post hoc (Ca suppl) Cohort study (Vit D; Dietary Ca) | Men Details were referred to original RCT (See Baron NEJM 1999 paper) | nd | 1988 (mentioned) – 1992 (inferred) | From Baron NEJM 1999 paper: Calcium Polyp Prevention Study | NCI and GlaxoSmithKlein | MC

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc.) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
15767334 | Baron 2005 | RCT- post hoc (Ca suppl) Cohort study (Vit D; Dietary Ca) | Cleveland Clinic Dartmouth–Hitchcock University of Iowa University of Minnesota University of North Carolina University of Southern California | 672 | 672 542 w/full PSA data (58% of 930) | 61.8 (8.7) | nd | 100 | African American: 5.4% | nd | From Baron NEJM 1999 paper: Had >1 histologically confirmed large-bowel adenoma removed within 3 months of enrollment but subsequently examined and judged free of polyps. In good heath. | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
15767334 | Baron 2005 | 25(OH)D, 1,25(OH) _ 2 _ D | | | | Competitive protein-binding assay (Quest Diagnostics). | Interbatch Pearson r for 25(OH)D = 0.95 Interbatch Pearson r for 1,25(OH) _ 2 _ D = 0.58 | nd | Nd | nd
15767334 | Baron 2005 | Dietary calcium intake | FFQ (Block, 1986) | nd (need to refer to NEJM 1999 paper) | no | nd | nd | | | 910 mg

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
15767334 | Baron 2005 | Ca | nd | CaCO3 3g (= elemental Ca 1200 mg) | Mean 44 mo (Compliance >/= 50%: 38%) | nd
| | placebo
Co-intervention(s) * : | | | Nd
Compliance/Adherence: | | | nd

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
15767334 | Baron 2005 | Secondary | Prostate cancer risk | Incident cases were sought through the periodic follow-up questionnaires. All reports of prostate cancer (by questionnaire or death certificate) were verified by review of hospital records.
15767334 | Baron 2005 | Secondary | Total serum PSA | Prostate-specific antigen measurements were determined using a solid-phase, two-site chemoluminescent immunometric assay (IMMULITE PSA, Diagnostic Products Co., Los Angeles, CA)

UI | Author Year | Comments
15767334 | Baron 2005 | PSA measurements only available among 544 men (81%)

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
| | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Log-calories
| | Demographics (e.g., age, gender, race, education)? | Yes
| | Anthropometrics (e.g., BMI, body weight, % body fat)? | no
| | Medical conditions
| | Medication
| | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | Season of blood draw | For 25(OH)D analysis only
| | Smoking and other life styles variables | no *
| | Other | Treatment (calcium supplement or placebo)

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | 95% Result CI | P btw
15767334 | Baron 2005 | Prostate cancer risk | Calcium carbonate supplement | 122.3 | 33 | 327 | RR Ca/Placebo | 0.83 | 0.52–1.32
15767334 | Baron 2005 | Prostate cancer risk | Placebo | 123.8 | 37 | 345 | RR Ca/Placebo | 0.83 | 0.52–1.32
15767334 | Baron 2005 | Prostate cancer risk | Calcium carbonate supplement | 48 | 9 | 327 | RR Ca/Placebo | 0.56 | 0.25–1.29
15767334 | Baron 2005 | Prostate cancer risk | Placebo | 48 | 15 | 345 | RR Ca/Placebo | 0.56 | 0.25–1.29
15767334 | Baron 2005 | PSA>4 ng | Calcium carbonate supplement | 48 | 14 | 279 | RR Ca/Placebo | 0.63 | 0.33–1.21
15767334 | Baron 2005 | PSA>4 ng | Placebo | 48 | 21 | 263 | RR Ca/Placebo | 0.63 | 0.33–1.21
15767334 | Baron 2005 | PSA>6 ng | Calcium carbonate supplement | 48 | 10 | 279 | RR Ca/Placebo | 0.73 | 0.32–1.63
15767334 | Baron 2005 | PSA>6 ng | Placebo | 48 | 13 | 263 | RR Ca/Placebo | 0.73 | 0.32–1.63

* Example: OR Ca/placebo

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline CI/SE/SD * | Final or Delta ** | Final or Delta CI/SE/SD * | Net difference | Net difference CI/SE/SD * | P between
15767334 | Baron 2005 | PSA change | ng/mL | Calcium carbonate supplement | 48 | 263 | 1.72 | 2.93 | +0.28 | 0.19 | −0.25 | nd | 0.34
15767334 | Baron 2005 | PSA change | ng/mL | Placebo | 48 | 279 | 1.88 | 2.52 | +0.53 | 0.18

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases | No. of Non-cases | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD | P between groups ** | P for trend ****
15767334 | Baron 2005 | Prostate cancer risk | Baseline dietary calcium intake–tertile 1 | | <675.2 | nd | nd | adjusted | RR | 1.0 (Ref) | | nd | 0.51
| | | Baseline dietary calcium intake–tertile 2 | | 675.2–990.8 | nd | nd | | | 1.48 | 0.81–2.70
| | | Baseline dietary calcium intake–tertile 3 | | >990.8 | nd | nd | | | 1.20 | 0.64–2.23
15767334 | Baron 2005 | Prostate cancer risk | Baseline 25(OH)D–tertile 1 | | <25.2 ng/mL | nd | nd | adjusted | RR | 1.0 (Ref) | | nd | 0.70
| | | Baseline 25(OH)D–tertile 2 | | 25.2–34 ng/mL | nd | nd | | | 1.22 | 0.66–2.26
| | | Baseline 25(OH)D–tertile 3 | | >34.0 ng/mL | nd | nd | | | 1.32 | 0.72–2.43
15767334 | Baron 2005 | Prostate cancer risk | Baseline 1,25(OH) _ 2 _ D–tertile 1 | | <36.4 pg/mL | nd | nd | adjusted | RR | 1.0 (Ref) | | nd | 0.92
| | | Baseline 1,25(OH) _ 2 _ D–tertile 2 | | 36.4–47.08 pg/mL | nd | nd | | | 1.10 | 0.55–1.83
| | | Baseline 1,25(OH) _ 2 _ D–tertile 3 | | >47.08 pg/mL | nd | nd | | | 1.02 | 0.57–1.82

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 =−8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
15767334 | Baron 2005 | Male subgroup of RCT | nd | nd | nd | Y (42/672=6%) | nd | Y | N | Y (but only some) | Y | C
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Inadequate adjustment for confounding; no data on number of cases per exposure category

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT– Parallel, RCT– Cross-over, RCT– Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
15767334 | Baron 2005 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | Y | a) Method reported? (y/n) | Y | a) One of the prespecified methods was used? (y/n) | n | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | a) Clear definition of outcome, including time of ascertainment? (y/n) | y | a) Prospective collection of data? (y/n) | y
15767334 | Baron 2005 | b) Sampling of population random or consecutive? (y/n) | y | b) Outcome assessor blinded to exposure measurement? (y/n) | n | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | b) Loss to follow-up <20%? (y/n) | y | b) Analysis was planned when cohort was formed? (y/n) | n
15767334 | Baron 2005 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | n | | | | | b) Justification of final adjusted model selection? (y/n) | n | c) Do the authors specify a primary outcome? (y/n) | y | c) Justification of sample size (includes sample size calculations)? (y/n) | n
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | This is a subgroup analysis from a RCT. Prostate cancer outcome was not planned outcome in the original RCT. No adjustment for other factors relevant to prostate cancer (like FH).

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

## Bertone- Johnson 2005

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
16103450 | Bertone- Johnson 2005 | Case- cohort study | 43 to 69 years old female registered nurses in the US who participated in the Nurses’ health cohort study and those who did not have cancer and had provided blood samples. | Those who had cancer before start of the study | Original cohort 1976 Study cohort 1989–1990 | Nurses’ health study | Gov | GR

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc.) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
16103450 | Bertone- Johnson 2005 | Case- cohort study | U.S. | 1459 735 with breast cancer 724 controls | 1425 (701 breast cancer and 724 controls) | 57 (7.0) | nd | 0% | ND | BMI at age 18=21.1 BMI at blood collection=25 | Post menopausal 68% Ever smokers 56% Family h/o breast cancer 17% Parity = 3 | Plasma 25 (OH) D at 1989–1990 31.5 ng/mL Plasma 1,25 OH2D = 33.5 ng/mL

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Background exposure data
16103450 | Bertone- Johnson 2005 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | RIA | N | ~3–10 y | ND

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
16103450 | Bertone- Johnson 2005 | Primary | Breast cancer risk | Risk of developing or newly diagnosed breast cancer
| | Secondary | Breast cancer risk by age <60y and ≥60y | Risk of developing or newly diagnosed breast cancer stratified by age groups

UI | Author Year | Comments
16103450 | Bertone-Johnson 2005 | Blood were withdrawn in 3 batches and analyzed by 3 different methods; 25(OH)D has different cut-offs for these 3 batches

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
16103450 | Bertone-Johnson 2005 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes; plasma alpha-carotene level, intakes of alcohol
16103450 | Bertone-Johnson 2005 | Demographics (e.g., age, gender, race, education)? | Yes (matched by age, menopausal status)
16103450 | Bertone-Johnson 2005 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes BMI at age 18
16103450 | Bertone-Johnson 2005 | Medical conditions | Family of breast cancer; benign breast disease
16103450 | Bertone-Johnson 2005 | Medication | Use of post menopausal hormones
16103450 | Bertone-Johnson 2005 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | ND
16103450 | Bertone-Johnson 2005 | Smoking and other life styles variables | Yes (intakes of alcohol)
16103450 | Bertone-Johnson 2005 | Other | Parity; age at first birth

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/ | Mean Ca level/dose | No. of Cases (Event) * | No. of Non- cases ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups *** | P for trend ****
16103450 | Bertone-Johnson 2005 | Breast cancer risk | 25(OH)D quintile 1 | ≤20 ng/mL(1 ^ st ^ batch) ≤28 (2 ^ nd ^ batch) ≤18 (3 ^ rd ^ batch) | Nd | 159 | 138 | Adjusted (both analyses available) | RR | 1.0 | | | .04 (only data available for unadjusted analyses)
16103450 | Bertone-Johnson 2005 | Breast cancer risk | 25(OH)D quintile 2 | 21 to 28 29 to 34 19 to 24 | | 149 | 129 | Adjusted | RR | 0.95 | 0.66–1.36 | nd
16103450 | Bertone-Johnson 2005 | Breast cancer risk | 25(OH)D quintile 3 | 29 to 33 35 to 39 25 to 29 | Nd | 125 | 141 | Adjusted | RR | 0.74 | 0.51–1.06 | nd
16103450 | Bertone-Johnson 2005 | Breast cancer risk | 25(OH)D quintile 4 | 34 to 39 40 to 47 30 to 36 | | 144 | 152 | Adjusted | RR | 0.80 | 0.58–1.11 | nd
16103450 | Bertone-Johnson 2005 | Breast cancer risk | 25(OH)D quintile 5 | ≥40 ng/mL ≥48 ng/mL ≥37 ng/mL | | 124 | 141 | Adjusted | RR | 0.73 | 0.49–1.07 | nd
16103450 | Bertone-Johnson 2005 | Breast cancer risk | 25(OH)2 D quintile 1 | ≤28.5 ng/mL | | 138 | 127 | Adjusted | RR | 1.0 | | nd | 0.39
16103450 | Bertone-Johnson 2005 | Breast cancer risk | 25(OH)2D quintile 2 | 28.6 to 31.5 ng/mL | | 111 | 121 | Adjusted | RR | 0.68 | 0.46–1.02 | nd
16103450 | Bertone-Johnson 2005 | Breast cancer risk | 25(OH)2D quintile 3 | 31.6 to 34.3 | | 117 | 122 | Adjusted | RR | 0.73 | 0.50–1.07 | nd
16103450 | Bertone-Johnson 2005 | Breast cancer risk | 25(OH)2D quintile 4 | 34.4 to 38.1 | | 123 | 122 | Adjusted | RR | 0.78 | 0.53–1.14 | nd
16103450 | Bertone-Johnson 2005 | Breast cancer risk | 25(OH)2D quintile 5 | ≥38.2 | | 129 | 126 | Adjusted | RR | 0.76 | 0.52–1.11 | nd

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

Subgroup Analyses

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/ | Mean Ca level/dose | No. of Cases (Event)* | No. of Non- cases ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups*** | P for trend****
16103450 | Bertone-Johnson 2005 | Breast cancer risk | 25(OH)D quintile 1 Stratified by <60y age at blood collection | ≤20 ng/mL(1 ^ st ^ batch) ≤28(2 ^ nd ^ batch) ≤18 (3 ^ rd ^ batch) | Nd | 97 | 94 | Adjusted (both analyses available) | RR | 1.0 | | | 0.20
16103450 | Bertone-Johnson 2005 | Breast cancer risk | 25(OH)D quintile 2 Stratified by <60y age at blood collection | 21 to 28 29 to 34 19 to 24 | | 84 | 86 | Adjusted | RR | 0.96 | 0.62–1.49 | nd
16103450 | Bertone-Johnson 2005 | Breast cancer risk | 25(OH)D quintile 3 Stratified by age <60y at blood collection | 29 to 33 35 to 39 25 to 29 | Nd | 77 | 87 | Adjusted | RR | 0.80 | 0.51–1.26 | nd
16103450 | Bertone-Johnson 2005 | Breast cancer risk | 25(OH)D quintile 4 Stratified by age<60y at blood collection | 34 to 39 40 to 47 30 to 36 | | 90 | 102 | Adjusted | RR | 0.85 | 0.55–1.32 | nd
16103450 | Bertone-Johnson 2005 | Breast cancer risk | 25(OH)D quintile 5 Stratified by age <60y at blood collection | ≥40 ng/mL ≥48 ng/mL ≥37 ng/mL | | 70 | 76 | Adjusted | RR | 0.92 | 0.57–1.48 | nd
16103450 | Bertone-Johnson 2005 | Breast cancer risk | 25(OH)D quintile 1 Stratified by ≥60y age at blood collection | ≤20 ng/mL(1 ^ st ^ batch) ≤28 (2 ^ nd ^ batch) ≤18 (3 ^ rd ^ batch) | | 62 | 47 | Adjusted | RR | 1.0 | | | 0.03
16103450 | Bertone-Johnson 2005 | Breast cancer risk | 25(OH)D quintile 2 Stratified by ≥60y age at blood collection | 21 to 28 29 to 34 19 to 24 | | 65 | 49 | Adjusted | RR | 1.07 | 0.60–1.92
16103450 | Bertone-Johnson 2005 | Breast cancer risk | 25(OH)D quintile 3 Stratified by age ≥60y at blood collection | 29 to 33 35 to 39 25 to 29 | | 48 | 57 | Adjusted | RR | 0.64 | 0.35–1.16
16103450 | Bertone-Johnson 2005 | Breast cancer risk | 25(OH)D quintile 4 Stratified by age ≥60y at blood collection | 34 to 39 40 to 47 30 to 36 | | 54 | 55 | Adjusted | RR | 0.68 | 0.38–1.24
16103450 | Bertone-Johnson 2005 | Breast cancer risk | 25(OH)D quintile 5 Stratified by age ≥60y at blood collection | ≥40 ng/mL ≥48 ng/mL ≥37 ng/mL | | 54 | 71 | Adjusted | RR | 0.57 | 0.31–1.04
16103450 | Bertone-Johnson 2005 | Breast cancer risk | 25(OH)2 D quintile 1 Stratified by ≥60y age at blood collection | ≤28.5 ng/mL | | 60 | 49 | Adjusted | RR | 1.0 | | nd | 0.23
16103450 | Bertone-Johnson 2005 | Breast cancer risk | 25(OH)2D quintile 2 Stratified by ≥60y age at blood collection | 28.6 to 31.5 ng/mL | | 55 | 53 | Adjusted | RR | 0.76 | 0.42–1.38 | nd
16103450 | Bertone-Johnson 2005 | Breast cancer risk | 25(OH)2D quintile 3 Stratified by ≥60y age at blood collection | 31.6 to 34.3 | | 50 | 38 | Adjusted | RR | 1.0 | 0.53–1.88 | nd
16103450 | Bertone-Johnson 2005 | Breast cancer risk | 25(OH)2D quintile 4 Stratified by ≥60y age at blood collection | 34.4 to 38.1 | | 39 | 47 | Adjusted | RR | 0.61 | 0.32–1.15 | nd
16103450 | Bertone-Johnson 2005 | Breast cancer risk | 25(OH)2D quintile 5 Stratified by ≥60y age at blood collection | ≥38.2 | | 53 | 51 | Adjusted | RR | 0.72 | 0.40–1.32 | nd

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
16103450 | Bertone-Johnson 2005 | a) Eligibility criteria clear? (y) | y | a) Exposure assessor blinded to outcome info? (y/n) | na | a) Method reported? (y/n) | na | a) One of the prespecified methods *** was used? (y/n) | y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | na | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | a) Clear definition of outcome, including time of ascertainment? (y/n) | y | a) Prospective collection of data? (y/n) | y
16103450 | Bertone-Johnson 2005 | b) Sampling of population random or consecutive? (n) | n | b) Outcome assessor blinded to exposure measurement? (y/n) | na | b) Food composition database or suppl composition reported? (y/n) na | na | Time from sample collection to sample analysis reported? (y/n) | y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | na | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | b) Loss to follow-up <20%? (y/n) | y | b) Analysis was planned when cohort was formed? (y/n) | n
16103450 | Bertone-Johnson 2005 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | na | | | | | b) Justification of final adjusted model selection? (y/n) | y | c) Do the authors specify a primary outcome? (y/n) | y | c) Justification of sample size (includes sample size calculations)? (y/n) | na
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | 3 different cut-off thresholds for vitamin D levels. Some of those with cancers were not analyzed, no explanation provided

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Bjorkman 2008

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17965037 | Bjorkman 2008 | RCT | Age ≥65 years, chronically impaired mobility, stable general condition, and no known present disease (except osteoporosis) or medication (vitamin D supplements, glucocorticoids, antiepileptics, etc.) affecting calcium or bone metabolism. | Markedly elevated creatinine levels (>125 umol/l), hypercalcemia (ionized calcium >1.32 mmol/l), hypothyroidism (thyrotopin >5.3 mU/l) or hyperthyroidism (thyrotropin<0.2 mU/L) | September to December 2005 | nd | A special governmental subsidy | MC

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …cetc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …cetc.)
17965037 | Bjorkman 2008 | RCT | Helsinki, Finland 60° 10′ North | 218 | 218 | 84.5 | 65–104.3 | 18.4 | nd | nd | All required assistance of >2 persons in almost all activities of daily living. Mean GFR = 64.3, ranged from 17 to 163. 67% had dementia; 43% had cerebrovascular disease; 14% had hip fracture | Frail and chronically bedridden

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
17965037 | Bjorkman 2008 | 25(OH)D | | | | HPLC | Within assay CV=5.6% at 21.6 nmol/l (n=14); 3.7% at 138 nmol/l (n=15). The total CV=7.3% at 16.4 nmol/l (n=12) 5.7% at 167 nmol/l (n=15) | nd | nd | 23 (ranged 9–60) nmol/l
17965037 | Bjorkman 2008 | Dietary calcium intake | nd | nd | no | nd | | | | 500 mg/day

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
17965037 | Bjorkman 2008 | Cholecalciferol 400 IU/day | Cholecalciferol (Vigantol, Merck KGaA, Darmstadt, Germany 20,000 IU in Migliol oil). 26 drops=~0.84 mL oil was diluted 3-fold with Migliol oil | Vitamin D 400 IU/day (group II) | 6 months | Nd
17965037 | Bjorkman 2008 | Cholecalciferol 1200 IU/day | Cholecalciferol (Vigantol, Merck KGaA, Darmstadt, Germany 20,000 IU in Migliol oil) | Vitamin D 1200 IU/day (group III) | 6 months | nd
| | Placebo
Co-intervention(s) * : | | | Before the start of intervention, the use of dairy products was roughly evaluated to be insufficient among 40 patients (18%), who received a daily calcium carbonate substitution of 500 mg during the intervention.
Compliance/Adherence: | | | The oil was swallowed entirely in the presence of the nurse and given with a small amount of food or drink.

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17965037 | Bjorkman 2008 | Primary | 25(OH)D level | Changes from baseline to 6-month after vitamin D supplementation
| | secondary | mortality | All cause

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17965037 | Bjorkman 2008 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
17965037 | Bjorkman 2008 | Demographics (e.g., age, gender, race, education)? | no *
17965037 | Bjorkman 2008 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no *
17965037 | Bjorkman 2008 | Medical conditions
17965037 | Bjorkman 2008 | Medication
17965037 | Bjorkman 2008 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
17965037 | Bjorkman 2008 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no *
17965037 | Bjorkman 2008 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Event * | Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
17965037 | Bjorkman 2008 | All cause mortality | Placebo | 0 | | 9 | 68 | Crude | nd | | | 0.262
| | | Cholecalciferol | 400 IU/day | | 17 | 77
| | | Cholecalciferol | 1200 IU/day | | 10 | 73

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

≥2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure Category/Intervention Group | Crude or Adjusted analysis? | Mean Follow-up (months) | No. Analyzed | Baseline | Baseline CI/SE/SD * | Delta ** | Delta SD * | Net difference *** | Net difference CI/SE/SD * | P between groups ***
17965037 | Bjorkman 2008 | 25(OH)D | nmol/l | Placebo | Crude | 6 | 59 | | | +1.9 | 10.2 | | | <0.0001
| | | | Cholecalciferol 400 IU/d | | | 60 | | | +26.5 | 11.8
| | | | Cholecalciferol 1200 IU/d | | | 63 | | | +49.1 | 19.5

Duplicate one row per exposure category or intervention group. Please write “nd” if there was no data reported. DO NOT LEAVE BLANK.

* Please choose one and delete the others

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
17965037 | Bjorkman 2008 | Most common causes of death in each group were pneumonia, Alzheimer’s disease and vascular dementia.

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
17965037 | Bjorkman 2008 | RCT - Parallel | nd | yes | NA | yes | nd | yes | yes | no | yes | A/B
Adverse Event(s): ** | | | | | | Nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | B for mortality outcome due to underpowered study and secondary outcome; A for changes in 25(OH)D outcome

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Blum 2008

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
18689559 | Blum 2008 | 2°/subgroup analysis of an RCT(?) | healthy ≥65 y; subgroup from a larger trial: those who did not travel to a latitude ≤35° N 3 mo prior to initial study visit and 3 mo prior to visit at year one. | conditions/medications related to bone; BMD >2SD below the reference mean; dietary Ca >1500 mg/d | nd | nd | NIH | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location(e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake…etc.)
18689559 | Blum 2008 | 2°/subgroup analysis of an RCT(?) | Boston, US, 42° N | 389 (original trial) | 257 (for this study) | 70 (4.9) | 65–86 | 47 | 97% white | 45% BMI 25–30 | healthy | Mean Vit D 189 IU/d; Ca 721 mg/d

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed information as possible on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
18689559 | Blum 2008 | 25(OH)D | | | | CPBA | n | n | subjects grouped by season of enrollment | Mean Vit D 189 IU/d
| | Dietary calcium intake | | | | | | | | Ca 721 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
18689559 | Blum 2008 | vit D + Ca | nd | vit D3 700 IU + Ca 500 mg/d | 3 y | nd
| | Placebo | | Placebo | 3 y | nd
Co-intervention(s) * :
Compliance/Adherence: | | | nd

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
18689559 | Blum 2008 | Primary | 25(OH)D at 1 y

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
18689559 | Blum 2008 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
18689559 | Blum 2008 | Demographics (e.g., age, gender, race, education)? | Yes * | age, sex
18689559 | Blum 2008 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes * | BMI
18689559 | Blum 2008 | Medical conditions
18689559 | Blum 2008 | Medication
18689559 | Blum 2008 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | Yes | season of visit
18689559 | Blum 2008 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no *
18689559 | Blum 2008 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline SD * | Delta ** | Delta SD * | Net difference | Net difference CI/SE/SD * | P between
18689559 | Blum 2008 | 25(OH)D | nmol/L | vit D + Ca | 1 y | 132 | 74.7 | 33.8 | +48.5 | 35.3 | 39.2 | | <0.01
18689559 | Blum 2008 | 25(OH)D | nmol/L | placebo | 1 y | 125 | 71.2 | 29.8 | +9.3 | 21.5

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
18689559 | Blum 2008 | subgroup analysis of an RCT | nd | nd | NA | nd | nd | n | y | y | n | C
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Unclear if there were subjects who met the inclusion criteria but were not selected in this study

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse events.

## Bodnar 2007

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17535985 | Bodnar 2007 | Nested case- control study | nulliparity; no preexisting medical conditions; bank serum <22 wk gestation | | 1997–2001 | Pregnancy Exposures & Preeclampsia Prevention Study | NIH | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location(e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake…etc.)
17535985 | Bodnar 2007 | Case- cohort study | Pittsburgh, PA | 1198 in the eligible cohort; 55 cases; 220 controls (not- matched) | 49 cases; 216 controls | 24 (est.) | 20–29 (est.) | 0 | 78% white (in cases); 68% white (in control) | prepregnancy BMI ≥25 = 58% of cases; 41% of controls | no preexisting medical conditions | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
17535985 | Bodnar 2007 | 25(OH)D | | | | ELISA | y; interassay CV 10.3% | 5–9 years | nd | nd
| | Dietary calcium intake

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17535985 | Bodnar 2007 | primary | preeclampsia | gestational HTN & proteinuria and return of all abnormalities by 12 wk postpartum

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17535985 | Bodnar 2007 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
17535985 | Bodnar 2007 | Demographics (e.g., age, gender, race, education)? | Yes * | race, education
17535985 | Bodnar 2007 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes * | prepregnancy BMI
17535985 | Bodnar 2007 | Medical conditions | | sample gestational age
17535985 | Bodnar 2007 | Medication
17535985 | Bodnar 2007 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | Yes | season
17535985 | Bodnar 2007 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no *
17535985 | Bodnar 2007 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

MEAN DATA

THIS SHOULD ONLY APPLY TO CASE-COHORT STUDIES THAT COMPARE BASELINE VIT D/CA LEVELS BETWEEN CASES (WITH DISEASE) AND CONTROLS (WITHOUT DISEASE)

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Mean 25(OH)D Level | Vit D level CI/SE/SD* | Mean Ca intake or Ca balance | Ca CI/SE/SD* | P between groups
17535985 | Bodnar 2007 | Cases: | 30 wk (est.) | adj | 49 | 45.4 | 38.6–53.4 | | | 0.01
| | Control: | 30 wk (est.) | | 216 | 53.1 | 47.4–59.9

Duplicate one table per outcome

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
17535985 | Bodnar 2007 | | early pregnancy 25(OH)-D <37.5 nmol/L was associated with an increased risk of preeclampsia (adj OR 5.0, 95%CI 1.7–14.1), independent of race, season, sample gestational age, prepregnancy BMI and education.

UI | Author Year | Comments for Results
17535985 | Bodnar 2007 | used specialized methods to control for unmeasured confounding (like calcium intake); ELISA could only detect 5–300 nmol/L of 25 (OH)D, sample measures outside of this range were excluded (3 samples).

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
17535985 | Bodnar 2007 | a) Eligibility criteria clear? (y/n) | y | a) Exposure assessor blinded to outcome info? (y/n) | n | a) Method reported? (y/n) | n | a) One of the prespecified methods *** was used? (y/n) | y | a) Level of the exposure in comparative categories(eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | a) Clear definition of outcome, including time of ascertainment? (y/n) | y | a) Prospective collection of data? (y/n) | y
17535985 | Bodnar 2007 | b) Sampling of population random or consecutive? (y/n) | n | b) Outcome assessor blinded to exposure measurement? (y/n) | n | b) Food composition database or suppl composition reported? (y/n) | n | Time from sample collection to sample analysis reported? (y/n) | y | a) Level of the exposure in comparative categories(eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | b) Loss to follow-up <20%? (y/n) | y | b) Analysis was planned when cohort was formed? (y/n) | n
17535985 | Bodnar 2007 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | NA | | | | | b) Justification of final adjusted model selection? (y/n) | n | c) Do the authors specify a primary outcome? (y/n) | y | c) Justification of sample size (includes sample size calculations)? (y/n) | n
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | did not adjust for some potential confounders

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Bolland 2008

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
18198394 | Bolland 2008 | RCT | Postmenopausal >5 yr, age ≥ 55 y, life expectancy >5 y, LS density within normal limits | Osteoporosis treatment, Ca supplementation, major organ disease, 25(OD)D<25 nmol/L | ~2000 | Same as Reid 2005 | Govt (suppl supplied by industry) | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...cetc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...cetc.)
18198394 | Bolland 2008 | RCT | Auckland, New Zealand 36° | 1471 | 1471 | 74 (~4.2) | ≥ 55 y | 0 | nd | BMI 26.4 | healthy | 25(OD)D≥ 25 nmol/L

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data ...etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
18198394 | Bolland 2008 | Dietary calcium intake | nd | nd | nd | nd | No | | nd | Dietary calcium 857 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
18198394 | Bolland 2008 | Ca supplement | Calcium citrate (Citracal) | 1 g (elemental) | 5 years | 2 × 200 mg before breakfast; 3 × 200 mg evening
| | Identical placebo
Co-intervention(s) * : | | | None
Compliance/Adherence: | | | Calcium: 396 (54%) alive, continuing followup, continuing intervention at 5 years. Overall compliance 55% Placebo: 443 (60%) alive, continuing followup, continuing intervention at 5 years. Overall compliance 58%

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
18198394 | Bolland 2008 | 1° (this analysis; 2° for original RCT) | Death | Family, hospital, and national records
| | 1° (this analysis; 2° for original RCT) | Sudden death | Standard criteria adjudicated by blinded cardiologist “Adjudicated” analysis used
| | 1° (this analysis; 2° for original RCT) | MI | Standard criteria adjudicated by blinded cardiologist “Adjudicated” analysis used
| | 1° (this analysis; 2° for original RCT) | Stroke | Standard criteria adjudicated by blinded neurologist “Adjudicated” analysis used
| | 1° (this analysis; 2° for original RCT) | CVD Composite (MI, Stroke, Sudden death) | composite “Adjudicated” analysis used

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

Did not data extract angina TIA or composite outcomes including these outcomes (reported by participants or family member; adjudicated data not reported by authors),

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
18198394 | Bolland 2008 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | No
18198394 | Bolland 2008 | Demographics (e.g., age, gender, race, education)? | Yes | But all ≥ 55 yo
18198394 | Bolland 2008 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No
18198394 | Bolland 2008 | Medical conditions | Yes | h/o outcomes
18198394 | Bolland 2008 | Medication | No
18198394 | Bolland 2008 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | No
18198394 | Bolland 2008 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | No
18198394 | Bolland 2008 | Other | No

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | Result | 95% CI | P btw
18198394 | Bolland 2008 | MI | Calcium | 5 yr | 31 | 732 | RR Ca/placebo | 1.49 | 0.86, 2.57 | NS
18198394 | Bolland 2008 | MI | Placebo | 5 yr | 21 | 739 | RR Ca/placebo | 1.49 | 0.86, 2.57 | NS
| | MI | Calcium | 5 yr | 11.1 | nd | Ratio of rates per 1000 person years | 1.67 | 0.98, 2.87 | .06
| | MI | Placebo | 5 yr | 6.6 | nd | Ratio of rates per 1000 person years | 1.67 | 0.98, 2.87 | .06
| | Stroke | Calcium | 5 yr | 34 | 732 | RR Ca/placebo | 1.37 | 0.83, 2.28 | NS
| | Stroke | Placebo | 5 yr | 25 | 739 | RR Ca/placebo | 1.37 | 0.83, 2.28 | NS
| | Stroke | Calcium | 5 yr | 11.4 | nd | Ratio of rates per 1000 person years | 1.45 | 0.88, 2.49 | NS
| | Stroke | Placebo | 5 yr | 7.8 | nd | Ratio of rates per 1000 person years | 1.45 | 0.88, 2.49 | NS
| | Sudden death | Calcium | 5 yr | 3 | 732 | RR Ca/placebo | 0.51 | 0.13, 2.01 | NS
| | Sudden death | Placebo | 5 yr | 6 | 739 | RR Ca/placebo | 0.51 | 0.13, 2.01 | NS
| | Sudden death | Calcium | 5 yr | 0.9 | nd | Ratio of rates per 1000 person years | 0.51 | 0.10, 2.04 | NS
| | Sudden death | Placebo | 5 yr | 1.8 | nd | Ratio of rates per 1000 person years | 0.51 | 0.10, 2.04 | NS
| | Composite | Calcium | 5 yr | 60 | 732 | RR Ca/placebo | 1.21 | 0.84, 29.2 | NS
| | Composite | Placebo | 5 yr | 50 | 739 | RR Ca/placebo | 1.21 | 0.84, 29.2 | NS
| | Composite | Calcium | 5 yr | 23.3 | nd | Ratio of rates per 1000 person years | 1.43 | 1.01, 2.04 | .04
| | Composite | Placebo | 5 yr | 16.3 | nd | Ratio of rates per 1000 person years | 1.43 | 1.01, 2.04 | .04

* Example: OR Ca/placebo

NOTE: RR analysis: No. of patients with events (not # of events) used.

NOTE: Ratio of rates analysis: rates per 1000 patient years extracted.

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
18198394 | Bolland 2008 | RR analysis: No. of patients with events (not # of events) used. Ratio of rates analysis: rates per 1000 patient years extracted.

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique(y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
18198394 | Bolland 2008 | RCT | Yes | Yes | NA | Yes | Yes | Yes | Yes | Partial | Mostly | B
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Since these are 2° outcomes (from original study perspective), fully adjusted analyses should have been performed. In addition, multiple methods for assessing outcomes (Tables 2, 3, 4) is confusing, making it unclear which outcome is most meaningful. Their approach or logic was not adequately described in Methods.

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Bolton-Smith 2007

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17243866 | Bolton-Smith 2007 | RCT | Healthy women ≥60 years of age were recruited to provide about equal numbers in the age groups 60–64, 65–69, 70–74, and ≥75 years | Clinical osteoporosis or chronic disease (e.g., DM, CVD, cancer, fat malabsorption syndromes), routine medication that interferes with vit K, vit D or bone metabolism (notably warfarin and steroids), and consumption of nutrient supplements that provided >30 ug vit K, 10 ug (400 IU) vit D, or 500 mg calcium daily. | nd | nd | UK Food Standards Agency | MC

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake...etc.)
17243866 | Bolton-Smith 2007 | RCT | UK | 123 | 106 | Vit D+Ca: 69.4 (6.4) Placebo: 67.8 (6.0) | ≥60 | 0 | nd | Mean BMI: 26 | Healthy | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
17243866 | Bolton- Smith 2007 | 25(OH)D | | | | Radioimmunoassay (RIA kit, DiaSorin, Wokingham, UK) | no | nd | Winter (baseline measure only); nd for follow-up measures | Vit D+Ca: 25.0 ug/L Placebo: 22.8 ug/L
17243866 | Bolton-Smith 2007 | Dietary calcium intake | FFQ, designed for studies of osteoporosis in Scottish women | nd | nd | Nd | | | | Vit D+Ca: 1078 mg/day Placebo: 1068 mg/day

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
17243866 | Bolton-Smith 2007 | 100 mg of elemental calcium + 10 ug of vitamin D _ 3 _ | A chewable tablet form contains calcium carbonate and vitamin vitamin D _ 3 _ (provided by Hoffmann-La Roche, Basel, Switzerland) | 100 mg of elemental calcium + 10 ug of vitamin D _ 3 _ | 2 years | 2 tablets per day with breakfast
| | placebo
Co-intervention(s) * : | | | None
Compliance/Adherence: | | | Good supplement adherence based on pill count (median, 99; IQE 97.3–99.8%). It should be noted that noncompliant women were excluded.

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17243866 | Bolton-Smith 2007 | nd | Femoral neck BMD | DEXA of the femur was carried out every 6 months using the same Lunar machine.
17243866 | Bolton-Smith 2007 | nd | 25(OH)D | Measured at baseline and yearly intervals. Assay performance was monitored against external quality assurance.

UI | Author Year | Comments
17243866 | Bolton-Smith 2007 | Original RCT had 4 groups: placebo, vit K supplement, vit D+Ca supplement, and vit K+vit D+Ca supplement. For the purpose of our review, only placebo and vitD+Ca groups were extracted.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17243866 | Bolton-Smith 2007 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | total energy intake, calcium and other nutrient intakes, serum markers of vitamin D and vitamin K status
17243866 | Bolton-Smith 2007 | Demographics (e.g., age, gender, race, education)? | Yes *
17243866 | Bolton-Smith 2007 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes *
17243866 | Bolton-Smith 2007 | Medical conditions
17243866 | Bolton-Smith 2007 | Medication
17243866 | Bolton-Smith 2007 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
17243866 | Bolton-Smith 2007 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes * (physical activity)
17243866 | Bolton-Smith 2007 | Other | bone area; markers of bone turnovers

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline SD * | Delta ** | Delta CI * | Net difference | Net difference CI/SE/SD * | P between
17243866 | Bolton-Smith 2007 | Femoral neck BMD | mg/cm ^ 2 ^ | Vit D+Ca | 24 | 50 | Nd | Nd | +1.9 | −6.5, 10.3 | +1.2 | nd | NS
17243866 | Bolton-Smith 2007 | Femoral neck BMD | mg/cm ^ 2 ^ | Placebo | 24 | 56 | nd | nd | +0.7 | −10.2, 11.6
17243866 | Bolton-Smith 2007 | 25(OH)D | ug/L | Vit D+Ca | 24 | 50 | 25.0 | 6.2 | Final: 29.8 | SD: 6.0 | nd | nd | <0.001
17243866 | Bolton-Smith 2007 | 25(OH)D | ug/L | Placebo | 24 | 56 | 22.8 | 6.1 | 19.5 | 5.3

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−” sign: e.g. +2.8 or −2.8

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
17243866 | Bolton-Smith 2007 | Data presented in the result table were unadjusted but the author stated that the adjusted results were similar to unadjusted results. For 25(OH)D outcome, it is unclear if seasonal variation was controlled for (by collecting blood samples during the same season at follow up)

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
17243866 | Bolton-Smith 2007 | RCT-Parallel | yes | yes | NA | yes | nd | no | yes | yes | yes | B
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Reasons for withdrawal included noncompliance or other violations of the inclusion criteria, low BMD necessitating further medical intervention, and dislike the tablets. Dropout rate=14%

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Bortolotti 2008

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
18842771 | Bortolotti 2008 | RCT | BMI > 27, Ca intakes <800 mg/d | BMI < 27, high intake of Ca | nd | nd | Nestec SA, Switzerland (subsidiary of Nestle SA) | MB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SEM) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) (SEM) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
18842771 | Bortolotti 2008 | RCT | Lausanne, Switzerland (latitude = 46 N) | 10 | 10 | 22.2 (1.2) | nd | 30% | nd | Weight(kg) = 78.1 (9.1) Height(m) = 1.65 (0.06) BMI(kg/m ^ 2 ^ ) = 28.5 (1.4) | Overweight/obese | Ca intakes < 800 mg/d

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed information as possible on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
18842771 | Bortolotti 2008 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | nd | nd | nd | nd
| | Dietary calcium intake | nd | nd | nd | Ca balance | n | | nd | Ca intake mg/d (SEM) = 586 (137)

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
18842771 | Bortolotti 2008 | Ca | Dairy Ca supplement – Arla Foods, Viby, Denmark. Natural milk mineral concentrate: 6% protein, 13% lactose, 74% ash, 6% moisture, and 24% Ca, present almost entirely as calcium phosphate. | 800 mg/d | 5 wks | Sachets were taken 2 times a day
| | placebo | Made of maltodextrin and filler. Made by Roquette, Lestrem, France | - | 5 wks | Sachets were taken 2 times a day
Co-intervention(s) * : | | | Subjects consumed their habitual low-Ca diet
Compliance/Adherence: | | | Authors state that compliance was assessed by counting the number of returned empty sachets. No specifics regarding compliance were provided.

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
18842771 | Bortolotti 2008 | 2° | weight

UI | Author Year | Comments
18842771 | Bortolotti 2008 | Study was a RCT crossover design in which 5 subjects received placebo and 5 received Ca for 5 wks. This was followed by a 10-week washout period before the 2 ^ nd ^ intervention period. Total study length was therefore 20 weeks. After 4 weeks of each intervention period, either 500 mg lactose or 300 mg slow-release caffeine was administered. After the 5 ^ th ^ week, the lactose or caffeine, whichever was not administered a week prior, was administered. This was done to explore possible synergistic effects between Ca and caffeine as far as energy expenditure and lipid oxidation.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
18842771 | Bortolotti 2008 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | no
18842771 | Bortolotti 2008 | Demographics (e.g., age, gender, race, education)? | no *
18842771 | Bortolotti 2008 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no *
18842771 | Bortolotti 2008 | Medical conditions | no
18842771 | Bortolotti 2008 | Medication | no
18842771 | Bortolotti 2008 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | no
18842771 | Bortolotti 2008 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no *
18842771 | Bortolotti 2008 | Other | no

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline SEM * | Final ** | Final SEM * | Net difference | Net difference CI/SE/SD * | P between
18842771 | Bortolotti 2008 | weight | kg | Ca | 1.25 | 10 | 78.1 | 9.1 | 80.0 | 3.2 | +0.4 | | NS
18842771 | Bortolotti 2008 | weight | kg | placebo | 1.25 | 10 | 78.1 | 9.1 | 79.6 | 3.0

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
18842771 | Bortolotti 2008 | RCT- crossover | nd/NA | nd | Y | Y | nd | nd | Y | NA | Y | B
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Weight loss was not 1° outcome and lactose/caffeine was administered during the study as an acute intervention. No information on allocation concealment or blinded outcome assessment

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT–Parallel, RCT–Cross-over, RCT–Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse events.

## Bostick 1993

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
8333412 | Bostick 1993 | Cohort study | - Women aged 55–69; - Resided in Iowa verified by driver’s license; - Responded to the baseline questionnaire (n=41837) | - Hx of cancer (excl. skin cancer) (n=3519); - >30 items on the FFQ blank (n=2299); - Implausibly high (>5000) or low (<600) energy intake (kcal/d) (n=291) | 1986 | Iowa Women’s Health Study | NCI | TTe

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location(e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake…etc.)
8333412 | Bostick 1993 | Cohort study | Iowa, US (40°23′ – 40°30′ N) | 41837 | 35216 | 61.5 (nd) | nd | 0% | nd | BMI=27.0 kg/m2 Height=64.1 inches Waist/hip=0.837 | nd | Total energy intake=1801.5 kcal/d Total Ca=1118.3 mg/d Total Vit D=411.7 IU/d Dietary fiber=20.4 g/d Total fat=68.7 g/d

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or1,25(OH) _ 2 _ D
8333412 | Bostick 1993 | Dietary calcium intake | FFQ (Harvard FFQ by Willet) | USDA Nutrient Database | Yes: reported in Munger et al. AJEpi 1992 | NA | NA | | nd | Total Ca=1118.3 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
8333412 | Bostick 1993 | Not explicitly described but the only outcome reported | Colon cancer | State Health registry of Iowa/SEER

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

# rectal cancer cases were excluded.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
8333412 | Bostick 1993 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes (total energy intake, total Vit E intake, low fat meat variable)
8333412 | Bostick 1993 | Demographics (e.g., age, gender, race, education)? | Yes (age, parity)
8333412 | Bostick 1993 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes (height)
8333412 | Bostick 1993 | Medical conditions | No
8333412 | Bostick 1993 | Medication | No
8333412 | Bostick 1993 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
8333412 | Bostick 1993 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | No
8333412 | Bostick 1993 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

# Simultaneous inclusion of vit D, (calcium,) milk product in the models yielded no material difference

# considered but omitted because of not reaching <0.1 statistically significant level: education, BMI, Waist/hip, physical activity, any type of Vit/mineral supplement, fat, fiber, vegetables, fruits, red meat, alcohol, and phosphorus.

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Ca dose | No. of Cases (Event) * | No. of Total person- year ** | Mean follow up, months | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups *** | P for trend ****
8333412 | Bostick 1993 | Colon cancer (total Ca intake [mg]) | Q1 | | <629 | 54 | 33473 | nd | Adj (age) | RR (HR) | 1.0 | Ref | Nd | 0.01
| | | Q2 | | 629–896 | 44 | 33477 | nd | | | 0.82 | 0.55–1.22 | Nd
| | | Q3 | | 897–1188 | 42 | 33465 | nd | | | 0.78 | 0.52–1.16 | Nd
| | | Q4 | | 1189– 1547 | 44 | 33565 | nd | | | 0.82 | 0.55–1.23 | nd
| | | Q5 | | 1548- | 28 | 33466 | nd | | | 0.52 | 0.33–0.82 | nd
8333412 | Bostick 1993 | Colon cancer (total Ca intake [mg]) | Q1 | | <629 | 54 | 33473 | nd | Adj (full multivariate model) | RR (HR) | 1.0 | Ref | Nd | 0.22
| | | Q2 | | 629–896 | 44 | 33477 | nd | | | 0.89 | 0.59–1.33 | Nd
| | | Q3 | | 897–1188 | 42 | 33465 | nd | | | 0.88 | 0.58–1.33 | Nd
| | | Q4 | | 1189–1547 | 44 | 33565 | nd | | | 0.97 | 0.63–1.50 | nd
| | | Q5 | | 1548- | 28 | 33466 | nd | | | 0.68 | 0.41–1.11 | nd

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

# full multivariate model listed in the confounders table.

## data on dietary calcium, supplemental calcium, total Vit D, dietary Vit D, supplemental Vit D, total dairy intake, and fat containing dairy intake were also presented but not extracted.

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
8333412 | Bostick 1993 | Follow up: over 5 years

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
8333412 | Bostick 1993 | a) Eligibility criteria clear? (y/n) | N/nd | a) Exposure assessor blinded to outcome info? (y/n) | nd | a) Method reported? (y/n) | y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given y (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | a) Clear definition of outcome, including time of ascertainment? (y/n) | n | a) Prospective collection of data? (y/n) | y
8333412 | Bostick 1993 | b) Sampling of population random or consecutive? (y/n) | n/nd | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | y | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given y (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | b) Loss to follow-up <20%? (y/n) | y <1% | b) Analysis was planned when cohort was formed? (y/n) | n
8333412 | Bostick 1993 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | | | | | | b) Justification of final adjusted model selection? (y/n) | y | c) Do the authors specify a primary outcome? (y/n) | nd | c) Justification of sample size (includes sample size calculations)? (y/n) | n
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Study designed for cancer incidence and mortality; not specifically for colon cancer; power calculation for colon cancer not stated; blinding for assessors not reported; confirmation of cancer cases by histology not reported; post-hoc analysis using an existing database.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Bostick 1999

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
9921960 | Bostick 1999 | Cohort study | Women 55–69 y, post-menstrual | Ischemic heart disease, incomplete FFQ, implausible energy intake (<600 or >5000 kcal/d) | 1986 | Iowa Women’s Health Study | NCI | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
9921960 | Bostick 1999 | Cohort study | Iowa ~42° | 34,486 | 34,486 | 61 | 55–69 | 0 | White ~100% | ~27 | Healthy | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
9921960 | Bostick 1999 | Dietary calcium intake | FFQ | nd | Yes Reliability coefficients 0.57–0.82 Validity coefficients 0.67 & 0.51 | NA | NA | | NA | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
9921960 | Bostick 1999 | 1° | Ischemic heart disease mortality | Health registry, death certificates, ICD-9 codes. Not validated

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
9921960 | Bostick 1999 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes | Total energy intake, dietary vitamin E, saturated fat intake (total Ca intake for supplemental Vit D analysis)
9921960 | Bostick 1999 | Demographics (e.g., age, gender, race, education)? | Yes | Age
9921960 | Bostick 1999 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI, waist:hip ratio
9921960 | Bostick 1999 | Medical conditions | Yes | DM
9921960 | Bostick 1999 | Medication | Yes | Estrogen
9921960 | Bostick 1999 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
9921960 | Bostick 1999 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | Smoking, EtOH, physical activity
9921960 | Bostick 1999 | Other | Yes | Education, marital status

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Vit D dose | Ca intake | No. of Cases (Event) * | N (person years) | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups *** | P for trend ****
9921960 | Bostick 1999 | IHD death | Total Ca intake Quartile 1 | | <696 | 127 | ~8621.5 (74,224) | 8 y | Adjusted | RR | 1.00 | -- | -- | .09
| | | Quartile 2 | | 696–1051 | 84 | ~8621.5 (74,497) | | | | 0.62 | 0.45, 0.85 | <.05
| | | Quartile 3 | | 1052–1425 | 94 | ~8621.5 (74,588) | | | | 0.75 | 0.55, 1.03 | >.05
| | | Quartile 4 | | >1425 | 82 | ~8621.5 (74,570) | | | | 0.67 | 0.47, 0.94 | <.05

Duplicate one row per exposure category or intervention group.36

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
9921960 | Bostick 1999 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | nd | a) Method reported? (y/n) | FFQ | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
9921960 | Bostick 1999 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | ?
9921960 | Bostick 1999 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | Y | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | No ascertainment of outcome “other studies have indicated that the validity of the IHD on death certificates is relatively high.”

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Braun 1995a

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
329893 | Braun 1995 | Case-cohort study | Cohort: a population-based registry of the residents in Washington county (Maryland) in 1974 with blood sample donation and filling in a short questionnaire Cases: histologically confirmed colon cancer diagnosed between 1984 and 1991 identified through the cancer registry in the county Controls: 2 matching participants without colon cancer (by the date of diagnosis of the case) per case from the same cohort | | 1974 | Washington County Cohort | nd | TTe

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
329893 | Braun 1995 | Case- cohort study | Washington, Maryland, USA 39 N | Cohort: 20,305 Cases: 61 Controls: 122 | Cases: 61 Controls: 122 | 55 (median) | nd | nd | nd | nd | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
329893 | Braun 1995 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | RIA (25-D) Radioreceptor assay (1,25-D) | Coefficients of variation: Interset, 14.1% (25-D) and 8.7% (1,25-D) Intraset, 8.9% (25-D) and 12.4% (1,25-D) | Nd (~18 y inferred, mean 14 y between sampling and diagnosis reported) | (Late) August though November | nd
| | Dietary calcium intake | nd | nd | nd | nd | nd | | | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
329893 | Braun 1995 | nd | Colon cancer | Washington county cancer registry with histological confirmation (unclear when)

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
329893 | Braun 1995 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | No
329893 | Braun 1995 | Demographics (e.g., age, gender, race, education)? | Yes | matching: age, race, sex
329893 | Braun 1995 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No
329893 | Braun 1995 | Medical conditions | No
329893 | Braun 1995 | Medication | No
329893 | Braun 1995 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | Yes | matching: date of blood sampling
329893 | Braun 1995 | Smoking and other life styles variables | No
329893 | Braun 1995 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

No adjusted analysis reported except for matching.

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean follow- up time | No. of Cases (Event) * | No. of Non- cases/Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI/SE/SD ** | P between groups *** | P for trend ****
329893 | Braun 1995 | Colon cancer | Q1 | <17.2 | 10–17 y (cases) | 61 | 122 | crude | OR | 1 (ref) | - | nd | 0.57
329893 | Braun 1995 | Colon cancer | Q2 | 17.2–20.6 | 10–17 y (cases) | 61 | 122 | crude | OR | 0.3 | 0.1–1.0 | nd | 0.57
329893 | Braun 1995 | Colon cancer | Q3 | 20.7–24.6 | 10–17 y (cases) | 61 | 122 | crude | OR | 0.5 | 0.2–1.5 | nd | 0.57
329893 | Braun 1995 | Colon cancer | Q4 | 24.7–30.1 | 10–17 y (cases) | 61 | 122 | crude | OR | 0.7 | 0.2–2.0 | nd | 0.57
329893 | Braun 1995 | Colon cancer | Q5 | >30.1 | 10–17 y (cases) | 61 | 122 | crude | OR | 0.4 | 0.1–1.4 | nd | 0.57
329893 | Braun 1995 | Colon cancer [25(OH)D (ng/ml)] | Q1 | <26.6 | 10–17 y (cases) | 61 | 122 | crude | OR | 1 (ref) | - | nd | 0.88
329893 | Braun 1995 | Colon cancer [25(OH)D (ng/ml)] | Q2 | 26.6–32.5 | 10–17 y (cases) | 61 | 122 | crude | OR | 1.6 | 0.6–4.4 | nd | 0.88
329893 | Braun 1995 | Colon cancer [25(OH)D (ng/ml)] | Q3 | 32.6–36.0 | 10–17 y (cases) | 61 | 122 | crude | OR | 1.1 | 0.4–3.3 | nd | 0.88
329893 | Braun 1995 | Colon cancer [25(OH)D (ng/ml)] | Q4 | 36.1–41.3 | 10–17 y (cases) | 61 | 122 | crude | OR | 1.1 | 0.4–3.3 | nd | 0.88
329893 | Braun 1995 | Colon cancer [25(OH)D (ng/ml)] | Q5 | >41.3 | 10–17 y (cases) | 61 | 122 | crude | OR | 1.1 | 0.4–3.2 | nd | 0.88
329893 | Braun 1995 | Colon cancer [1,25(OH)D (pg/ml)] | Q1 | <17.2 | 10–17 y (cases) | 61 | 122 | crude | OR | 1 (ref) | - | nd | 0.57
329893 | Braun 1995 | Colon cancer [1,25(OH)D (pg/ml)] | Q2 | 17.2–20.6 | 10–17 y (cases) | 61 | 122 | crude | OR | 0.3 | 0.1–1.0 | nd | 0.57
329893 | Braun 1995 | Colon cancer [1,25(OH)D (pg/ml)] | Q3 | 20.7–24.6 | 10–17 y (cases) | 61 | 122 | crude | OR | 0.5 | 0.2–1.5 | nd | 0.57
329893 | Braun 1995 | Colon cancer [1,25(OH)D (pg/ml)] | Q4 | 24.7–30.1 | 10–17 y (cases) | 61 | 122 | crude | OR | 0.7 | 0.2–2.0 | nd | 0.57
329893 | Braun 1995 | Colon cancer [1,25(OH)D (pg/ml)] | Q5 | >30.1 | 10–17 y (cases) | 61 | 122 | crude | OR | 0.4 | 0.1–1.4 | nd | 0.57
329893 | Braun 1995 | Colon cancer [25(OH)D (ng/ml)] | Q1 | <26.6 | 10–17 y (cases) | 61 | 122 | crude | OR | 1 (ref) | - | nd | 0.88
329893 | Braun 1995 | Colon cancer [25(OH)D (ng/ml)] | Q2 | 26.6- | 10–17 y (cases) | 61 | 122 | crude | OR | 1.6 | 0.6–4.5 | nd | 0.88

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

MEAN DATA

THIS SHOULD ONLY APPLY TO CASE-COHORT STUDIES THAT COMPARE BASELINE VIT D/CA LEVELS BETWEEN CASES (WITH DISEASE) AND CONTROLS (WITHOUT DISEASE)

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Mean 25(OH)D Level | Vit D level SD* | Mean Ca intake or Ca balance | Ca CI/SE/SD* | P between groups
329893 | Braun 1995 | Cases: | ~18–20 y | crude | 61 | 23.6 | 9.2 | nd | nd | nd
329893 | [25(OH)D] | Control: | ~18–20 y | crude | 122 | 34.7 | 7.9 | nd | nd | nd
329893 | Braun 1995 | Cases: | ~18–20 y | crude | 61 | 23.2 | 7.8 | nd | nd | nd
329893 | [1,25(OH)D] | Control: | ~18–20 y | crude | 122 | 34.6 | 10.0 | nd | nd | nd

Duplicate one table per outcome

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
329893 | Braun 1995 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | Y | a) Method reported? (y/n) | NA | a) One of the prespecified methods *** was used? (y/n) | Y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
329893 | Braun 1995 | b) Sampling of population random or consecutive? (y/n) | nd | b) Outcome assessor blinded to exposure measurement? (y/n) | N | b) Food composition database or suppl composition reported? (y/n) | NA | Time from sample collection to sample analysis reported? (y/n) | N | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | nd
329893 | Braun 1995 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | NA | | | | | b) Justification of final adjusted model selection? (y/n) | NA | c) Do the authors specify a primary outcome? (y/n) | N | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade(A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | No clear inclusion (and selection) process of participants, probably post-hoc analysis of already available database. No reports on verification of cancer diagnosis or adjustments of family history. How often participants were excluded due to unavailability of blood samples is also unclear.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Braun 1995b

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
7612803 | Braun 1995 | Case-cohort study | Resident of Washington County, MD. Serum sample stored. | None (implied) | 1974 | (Washington County) | nd Corresponding/lead author is NCI employee | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc.) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
7612803 | Braun 1995 | Case- cohort study | Washington County, MD 39.7° (39° 42’) | 183 (61 cases, 122 controls) | 183 | Mode 55–64 (51%) | <45–75+ | 100% | White 100% | nd | No prostate cancer at baseline (pre-1980) | <5% with baseline 25(OH)D <15 ng/mL

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data ...etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
7612803 | Braun 1995 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | 25D: RIA ( ^ 125 ^ I) (Hollis 1993) 1,25D: Radioreceptor assay (Hollis 1986) | 25D: CV 11.1% interset; 22.0% intraset 1,25D: CV 14.3% interset; 21.3% intraset | ~18–20 yr | (Late) August through November | nd
| | Dietary calcium intake

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
7612803 | Braun 1995 | Primary (in post hoc analysis, maybe not for primary analysis) | Prostate cancer | Diagnosed 1980–1992, 6–18 y after blood sample Cancer registry
| | | Prostate cancer severity of disease | Method of diagnosis: Less severe: incidental finding on TURP More severe: other cases

UI | Author Year | Comments
7612803 | Braun 1995 | Blood samples drawn only from August-November

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
7612803 | Braun 1995 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | None
7612803 | Braun 1995 | Demographics (e.g., age, gender, race, education)? | Yes | Age (matched & subgroup analysis) (all male, White)
7612803 | Braun 1995 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No
7612803 | Braun 1995 | Medical conditions | No
7612803 | Braun 1995 | Medication | No
7612803 | Braun 1995 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | Month commented on | Unclear if used in any analysis
7612803 | Braun 1995 | Smoking and other life styles variables | No
7612803 | Braun 1995 | Other | | “Severity of disease”

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non- cases (controls) ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups *** | P for trend ****
7612803 | Braun 1995 | Prostate cancer [25(OH)D] | Q1 | <24.1 | nd | 7 | 24 | crude | OR | 1.0 (ref) | - | nd | 0.60
7612803 | Braun 1995 | Prostate cancer [25(OH)D] | Q2 | 24.1–29.5 | nd | 17 | 25 | crude | OR | 2.3 | 0.7–7.8 | nd | 0.60
7612803 | Braun 1995 | Prostate cancer [25(OH)D] | Q3 | 29.6–35.4 | nd | 16 | 24 | crude | OR | 2.3 | 0.7–7.7 | nd | 0.60
7612803 | Braun 1995 | Prostate cancer [25(OH)D] | Q4 | 35.5–41.3 | nd | 4 | 25 | crude | OR | 0.6 | 0.1–2.5 | nd | 0.60
7612803 | Braun 1995 | Prostate cancer [25(OH)D] | Q5 | >41.3 | nd | 17 | 24 | crude | OR | 2.4 | 0.8–8.2 | nd | 0.60
7612803 | Braun 1995 | Prostate caner [25(OH)D] | Q1 | <24.1 | nd | 7 | 24 | crude | OR | 1.0 (ref) | - | nd | NS
| | | Q2 | >24.1 | | 54 | 98 | | | 1.9 | 0.7–5.5

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

MEAN DATA

THIS SHOULD ONLY APPLY TO CASE-COHORT STUDIES THAT COMPARE BASELINE VIT D/CA LEVELS BETWEEN CASES (WITH DISEASE) AND CONTROLS (WITHOUT DISEASE)

UI | Author Year | Outcome Group | Time between Baseline Exposure and Outcome Assessments | Crude or Adjusted analysis? | No. Analyzed | Mean 25(OH)D Level | Vit D level SD | Mean Ca intake or Ca balance | Ca CI/SE/SD* | P between groups
7612803 | Braun 1995 | Cases: | 18 y | Crude | 61 | 34.3 | 9.9 | | | NS
| | Control: | | | 122 | 33.2 | 10.8

Duplicate one table per outcome

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
7612803 | Braun 1995 | Prostate cancer, adjusted for “method of diagnosis” and age above or below median | “Did not differ significantly between cases and controls”

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
7612803 | Braun 1995 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | Y | a) Method reported? (y/n) | NA | a) One of the prespecified methods *** was used? (y/n) | Y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | No (1°) | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a)Prospective collection of data? (y/n) | Y
7612803 | Braun 1995 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | Y † | b) Food composition database or suppl composition reported? (y/n) | NA | Time from sample collection to sample analysis reported? (y/n) | +/− | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | No (1°) | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | ?
7612803 | Braun 1995 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | NA | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Small, underpowered. 1° analysis was not controlled for relevant factors. Other analysis poorly described. Limited applicability for prostate cancer assessment (no blacks).

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

† Cases and controls chosen prior to Vit D level assessment

## Brooke 1980, Maxwell 1981

6793058; 6989438 ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
6793058 6989438 | Maxwell1981; Brooke 1980 | RCT | pregnant Asians | | nd | | government | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc.) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
6793058 | Maxwell 1981 | RCT | London, UK | 126 | 126 | nd | nd | 0 | Asians | weight at 3 ^ rd ^ trimester: 63.7 Kg | nd | 25(OH)D level at 28–32 wk: 20.1 nmol/L; ~25% vegetarians

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
6793058 | Maxwell 1981 | 25(OH)D | | | | nd | nd | | nd | 25(OH)D level at 28–32 wk: 20.1 nmol/L
| | Dietary calcium intake

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
6793058 | Maxwell 1981 | calciferol | | 1000 IU/d | 3 ^ rd ^ trimester only
Co-intervention(s) * :
Compliance/Adherence:

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
6793058 | Maxwell 1981 | primary | weight gain 3 ^ rd ^ trimester
| | secondary | birth weight
6989438 | Brooke 1980 | | 25(OH)D in cord blood & maternal blood at term
| | | infant symptomatic hypocalcemia | <1.8 mmol/L

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
6793058 | Maxwell 1981 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
6793058 | Maxwell 1981 | Demographics (e.g., age, gender, race, education)? | no *
6793058 | Maxwell 1981 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no *
6793058 | Maxwell 1981 | Medical conditions
6793058 | Maxwell 1981 | Medication
6793058 | Maxwell 1981 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
6793058 | Maxwell 1981 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no *
6793058 | Maxwell 1981 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | Result | 95% CI | P btw
6793058 | Maxwell 1981 | infants with birth weight <2500 g | calciferol | | 7 | 59 | | | | NS
6793058 | Maxwell 1981 | infants with birth weight <2500 g | control | | 15 | 67 | | | | NS
6989438 | Brooke 1980 | infant with symptomatic hypocalcemia | calciferol | | 0 | 59 | | chi2=4.6 | | <0.01
6989438 | Brooke 1980 | infant with symptomatic hypocalcemia | control | | 5 | 67 | | chi2=4.6 | | <0.01

* Example: OR Ca/placebo

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline CI/SE/SD * | Final | Final SD * | Net difference | Net difference CI/SE/SD * | P between
6793058 | Maxwell 1981 | maternal weight gain 3 ^ rd ^ trimester | g/d | calciferol | | 59 | | | 63.3 | 20.7 | | | <0.001
6793058 | Maxwell 1981 | maternal weight gain 3 ^ rd ^ trimester | g/d | control | | 67 | | | 46.4 | 29.5
6793058 | Maxwell 1981 | infant birth weight | g | calciferol | | 59 | | | 3157 | 469 | | | NS
6793058 | Maxwell 1981 | infant birth weight | g | control | | 67 | | | 3034 | 524
6989438 | Brooke 1980 | infant birth length | cm | calciferol | | 59 | | | 49.7 | 0.3 | | | NS
6989438 | Brooke 1980 | infant birth length | cm | control | | 67 | | | 49.5 | 0.4
| Brooke 1980 | maternal term 25 (OH)D level | nmol/L | calciferol | | 59 | 20.2 | | 168 | 12.5 | | | nd
| Brooke 1980 | maternal term 25 (OH)D level | nmol/L | control | | 67 | 20.0 | | 16.2 | 2.7
| Brooke 1980 | cord 25 (OH)D level | nmol/L | calciferol | | 59 | | | 137.9 | 10.8 | | | nd
| Brooke 1980 | cord 25 (OH)D level | nmol/L | control | | 67 | | | 10.2 | 2.0

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
6793058 | Maxwell 1981 | Unclear how weight gain differences between groups were determined not due to edema.

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
6793058; 6989438 | Maxwell 1981; Brooke 1980 | RCT | nd | nd | NA | y | y | y | n | n | n | B
Adverse Event(s): **
Explanation for Overall Quality Grade (if not Grade A): | | | | | | study methodology not completely reported; small sample size

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT –Parallel, RCT –Cross-over, RCT –Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Brunner 2008

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
18755319 | Brunner 2008 | RCT-post hoc ** | Postmenopausal women (50 to 79 yrs old) | nd | 1993–1998 | WHI | NIH, National Heart, Lung and Blood Institute | JHL

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
18755319 | Brunner 2008 | RCT-post hoc | US 40 centers | 36,282 joined at the initial stage of the Ca/vitD trial, 33,067 joined at the first annual visit | 2928 had objective physical function measures | nd | 50–79 yr | 0 | nd | nd | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed information as possible on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
18755319 | Brunner 2008 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | nd | nd | nd | nd
18755319 | Brunner 2008 | Dietary calcium intake | nd | nd | nd | nd | nd | | nd | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
18755319 | Brunner 2008 | Ca+VitD | 500mg calcium carbonate + 200IU vitD3 (by Glaxo SmithKline, Bensalem, PA) | 1000mg calcium carbonate + 400IU vitD3 | Average 7.1 yrs | two times a day
| | Placebo
Co-intervention(s) * : | | | Hormone therapy, dietary modification
Compliance/Adherence: | | | No information on adherence rate (however, adherence was assessed at least annually from the weight of remaining pills along with a structured interview.)

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
18755319 | Brunner 2008 | Secondary | Grip strength | Two measurements were made in the dominant hand with staff coaching for maximal performance (Jamar hand dynamometer; Lafayette Instruments)
18755319 | Brunner 2008 | Secondary | Chair stands | Conducted if the subject was able to stand at least once without using hands/arms from a straight-backed, nonpadded, flat-seated, armless chair. Two 15-second trials of repeated chair stands were performed with arms folded across the chest with a 1- to 2-minute rest in between trials. Counted as the participant arose, and counts for both trials recorded.
18755319 | Brunner 2008 | Secondary | Timed walk | The timed walk utilized a course marked on the floor with end lines 6m apart and “X” marked just beyond each end line. Participants used ambulatory aids as needed, walking at usual speed to one X with a second trial performed to the other X. The result was recorded as number of seconds from start to when a foot completely crossed the end line.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
18755319 | Brunner 2008 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes | Total Ca intake <600mg **
18755319 | Brunner 2008 | Demographics (e.g., age, gender, race, education)? | Yes * | Age (continuous), age 70 years or older ** , Asian or white ethnicity **
18755319 | Brunner 2008 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes * | Weight <127 lb **
18755319 | Brunner 2008 | Medical conditions | | History of two or more falls in past year; relative who broke bone before age 40; history of any fracture **
18755319 | Brunner 2008 | Medication | | Never used hormones **
18755319 | Brunner 2008 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
18755319 | Brunner 2008 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes * | Current smoker **
18755319 | Brunner 2008 | Other | | Treatment arm in the hormone therapy and dietary modification trials

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

** Fracture risk score

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline SD * | Delta ** | Delta SD * | Net difference | Net difference SE * | P between
18755319 | Brunner 2008 | Grip strength (year 2) | Kg | CaD | 24 months | 1334 | | | −1.20 | 5.63 | 0.06 | 0.21 | 0.790
18755319 | Brunner 2008 | Grip strength (year 2) | Kg | Placebo | 24 months | 1265 | | | −1.27 | 5.30
18755319 | Brunner 2008 | Grip strength (year 5) | Kg | CaD | 60 months | 1185 | 22.81 | 5.78 | −2.49 | 5.81 | 0.15 | 0.24 | 0.524
18755319 | Brunner 2008 | Grip strength (year 5) | Kg | Placebo | 60 months | 1162 | 22.96 | 5.75 | −2.64 | 5.69
18755319 | Brunner 2008 | Chair stands (year 2) | Counts | CaD | 24 months | 1250 | | | −0.09 | 1.55 | 0.03 | 0.06 | 0.623
18755319 | Brunner 2008 | Chair stands (year 2) | Counts | Placebo | 24 months | 1188 | | | −0.12 | 1.60
18755319 | Brunner 2008 | Chair stands (year 5) | Counts | CaD | 60 months | 1065 | 6.52 | 1.87 | −0.38 | 1.81 | 0.04 | 0.08 | 0.603
18755319 | Brunner 2008 | Chair stands (year 5) | Counts | Placebo | 60 months | 1053 | 6.63 | 1.82 | −0.43 | 1.81
18755319 | Brunner 2008 | Timed walk (year 2) | seconds | CaD | 24 months | 1298 | | | +0.11 | 7.08 | −0.12 | 0.27 | 0.580
18755319 | Brunner 2008 | Timed walk (year 2) | seconds | Placebo | 24 months | 1238 | | | +0.23 | 6.38
18755319 | Brunner 2008 | Timed walk (year 5) | seconds | CaD | 60 months | 1160 | 6.5 | 5.51 | +0.26 | 6.28 | −0.54 | 0.26 | 0.030
18755319 | Brunner 2008 | Timed walk (year 5) | seconds | Placebo | 60 months | 1141 | 6.19 | 4.64 | +0.81 | 6.43

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−” sign: e.g. +2.8 or −2.8

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
18755319 | Brunner 2008 | Only those women who were at least 80% adherent to study pills were examined in a subgroup analysis (data not shown). No substantial differences in physical functioning related to treatment assignment were found.

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
18755319 | Brunner 2008 | RCT-Parallel | nd | nd | n | nd | nd | y | y | y | y | C
Adverse Event(s): ** | | | | | | Nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Different number of participants who had objective physical function measures. Only small fraction of women had such data from WHI. No information on blinded outcome assessment. Referred to original design paper for RCT methodology.

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse events.

## Burleigh 2007

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17656420 | Burleigh 2007 | RCT | Patients were aged 65 years or over | Subjects with hypercalcemica, urolithiasis or renal dialysis therapy, patients who were terminal orbed-bound with a reduced Glasgow Coma Scale (GCS), those already prescribed calcium and vitamin D supplements, and those who were deemed nil by mouth at time of admission. | nd | nd | Nd | JHL

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
17656420 | Burleigh 2007 | RCT | Scotland (55° 57′ N) | 205 | 199 | 83.0 (7.6) | nd | 40% | nd | Under weight 40% Normal weight 50% Overweight 10% | Inpatient with high levels of comorbidity, mortality and polypharmacy | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
17656420 | Burleigh 2007 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | Using the Nicholas Advantage Analyser (Nicholas Institute Diagnostics, San Juan Capitrano, California, USA) | n | nd | nd | 25(OH)D 22.0 nmol/L
17656420 | Burleigh 2007 | Dietary calcium intake | nd | nd | nd | nd | nd | | nd | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
17656420 | Burleigh 2007 | VitD+Ca | cholecalciferol +calcium carbonate | 800iu cholecalciferol +1200mg calcium carbonate | The intervention was continued until time of patient discharge or death. Median length of hospital inpatient stay=30days | Once daily
17656420 | Burleigh 2007 | Ca | calcium carbonate | 1200mg calcium carbonate | Continued until time of patient discharge or death. Median length of hospital inpatient stay=30days | Once daily
Co-intervention(s) * : | | | nd
Compliance/Adherence: | | | Control group=87%, Intervention group=89%, compliance method – a percentage (total study drug taken/total study drug prescribed, as recorded in drug prescription charts)

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17656420 | Burleigh 2007 | Primary | Fall | Defined as the patient unintentionally coming to rest on the ground, or other lower level, other than as a consequence of sustaining violence or an epileptic seizure, documented by ward nursing staff in an official accident
17656420 | Burleigh 2007 | primary | fracture | Any fracture incurred during the inpatient stay was verified in medical and nursing note

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder including matching factors) | Specific comments for confounders
17656420 | Burleigh 2007 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | | No statistical analysis of baseline characteristics between control and intervention group.
17656420 | Burleigh 2007 | Demographics (e.g., age, gender, race, education)? | no * | No statistical analysis of baseline characteristics between control and intervention group.
17656420 | Burleigh 2007 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no * | No statistical analysis of baseline characteristics between control and intervention group.
17656420 | Burleigh 2007 | Medical conditions | | No statistical analysis of baseline characteristics between control and intervention group.
17656420 | Burleigh 2007 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | | No statistical analysis of baseline characteristics between control and intervention group.
17656420 | Burleigh 2007 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no * | No statistical analysis of baseline characteristics between control and intervention group.
17656420 | Burleigh 2007 | Other | | No statistical analysis of baseline characteristics between control and intervention group.

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | Result | 95% CI | P btw
17656420 | Burleigh 2007 | Fall | VitD+Ca | Median 30 days (IQR 14.75–71.00) | 36 | 100 | RR VitD+Ca/Ca | 0.82 | 0.59–1.16 | 0.263
17656420 | Burleigh 2007 | Fall | Ca | Median 30 days (IQR 14.75–71.00) | 45 | 103 | RR VitD+Ca/Ca | 0.82 | 0.59–1.16 | 0.263
17656420 | Burleigh 2007 | Fracture | VitD+Ca | Median 30 days (IQR 14.75–71.00) | 1 | 100 | nd | | | NS
17656420 | Burleigh 2007 | Fracture | Ca | Median 30 days (IQR 14.75–71.00) | 3 | 103 | nd | | | NS

* Example: OR Ca/placebo

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
17656420 | Burleigh 2007 | VitD levels | VitD levels(nmol/l) increased in the treatment group, but not in the control group, but this did not reach statistical significance (median change in vitD in control group; 0.00 vs. intervention group; 2.00, Mann-Whitney U test P=0.113)

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
17656420 | Burleigh 2007 | RCT-parallel | y | y | NA | Y | Y | Y | Y | N | Y | C
Adverse Event(s): ** | | | | | | Two individuals developed hypercalcaemia.
Explanation for Overall Quality Grade (if not Grade A): | | | | | | No statistical analysis of baseline characteristics between control and intervention group, Intervention duration varied, Serum vit D analysis was performed in only 1 in 4 patients.

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Caan 2007

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17502530 | Caan 2007 | RCT | Women 50–79 y, postmenopausal | none | 1994–1999 | WHI | Govt | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
17502530 | Caan 2007 | RCT | US | 36282 | 36282 | nd | 50–79 | 0 | White 83% Black 9% Hispanic 4% AmInd 0.4% As/PacIs 2% | BMI <25 28% 25 to <30 35% 30 to <35 22% >35 14% | Healthy, post- menopausal | Total Ca intake <600 mg/d 20% 600 to <1200 41% ≥1200 39%

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
17502530 | Caan 2007 | Dietary calcium intake | WHI adaptation of Block FFQ | (see other article) | Yes (not reported here) | | | | | See previous table Total Ca 1150 mg/d Total cholecalciferol 9 μg/day

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
17502530 | Caan 2007 | Ca + Vit D | Ca carbonate Cholecalciferol | 1000 mg 400 IU | 7 years | 500 mg/200 IU 2x/day
| | Placebo | | | 7 years | 2x/day
Co-intervention(s) * : | | | Factorial design overlaid on HT vs placebo. Allowed to take calcium (up to 1000 mg/d) and cholecalciferol (up to 600 IU/d, then 1000 IU/d after 1999)
Compliance/Adherence: | | | Proportion consuming ≥80% of study medications at year 1 60%; through year 7 56–63% annually. At least 66% took 50% or more through year 7.

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17502530 | Caan 2007 | 2° (1° for this article) | Weight | Kg

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17502530 | Caan 2007 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes | Total Ca intake
17502530 | Caan 2007 | | | Total cholecalciferol intake
17502530 | Caan 2007 | | | Energy intake
17502530 | Caan 2007 | Demographics (e.g., age, gender, race, education)? | Yes | Age, race, education
17502530 | Caan 2007 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI, waist circumference
17502530 | Caan 2007 | Medical conditions | Yes | DM
17502530 | Caan 2007 | Medication | Yes | hormone replacement
17502530 | Caan 2007 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | No
17502530 | Caan 2007 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | Smoking, exercise
17502530 | Caan 2007 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline CI/SE/SD * | Final or Delta ** | Final or Delta CI/SE/SD * | Net difference | Net difference CI/SE/SD * | P between
17502530 | Caan 007 | Weight | Kg | Ca+D | 7 yr | 18129 | 76.0 | 16.9 | nd | | −0.13 | (−0.21, −0.05) | 0.001
17502530 | Caan 007 | Weight | Kg | Placebo | | 18055 | 75.9 | 17.1 | nd

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−” sign: e.g. +2.8 or −2.8

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline CI/SE/SD* | Final or Delta** | Final or Delta CI/SE/SD* | Net difference | Net difference CI | P between
17502530 | Caan 2007 | Weight | Kg | Ca+D | 7 yr | 50–54 y 2592 | nd | | nd | | −0.24 | −0.45, −0.03 | <0.05
17502530 | Caan 2007 | Weight | Kg | Placebo | | 2561 | nd | | nd
| | | | | | 55–59 y 4134 | nd | | nd | | −0.08 | −0.24, +0.09 | NS
| | | | | | 4135 | nd | | nd
| | | | | | 60–69 y 8276 | nd | | nd | | −0.15 | −0.27, −0.03 | <0.05
| | | | | | 8243 | nd | | nd
| | | | | | 70–79 y 3174 | nd | | nd | | −0.10 | −0.27, +0.09 | NS
| | | | | | 3167 | nd | | nd
| | | | | | | | | | | Overall (interaction), AGE | | NS
17502530 | Caan 2007 | Weight | Kg | Ca+D | 7 yr | White 15047 | nd | | nd | | −0.13 | −0.22, −0.04 | <0.05
17502530 | Caan 2007 | Weight | Kg | Placebo | | 15106 | nd | | nd
| | | | | | Black 1682 | nd | | nd | | −0.32 | −0.59, −0.06 | <0.05
| | | | | | 1635 | nd | | nd
| | | | | | Hispanic 789 | nd | | nd | | −0.08 | −0.48, +0.32 | NS
| | | | | | 718 | nd | | nd
| | | | | | Asian/PacIs 369 | nd | | nd | | +0.19 | −0.37, +0.75 | NS
| | | | | | 353 | nd | | nd
| | | | | | | | | | | Overall (interaction), ETHNICITY | | NS
17502530 | Caan 2007 | Weight | Kg | Ca+D | 7 yr | BMI<25 4974 | nd | | nd | | −0.08 | −0.23, +0.06 | NS
17502530 | Caan 2007 | Weight | Kg | Placebo | | 5117 | nd | | nd
| | | | | | BMI 25–30 6409 | nd | | nd | | −0.09 | −0.22, +0.04 | NS
| | | | | | 6327 | nd | | nd
| | | | | | BMI 30–35 4037 | nd | | nd | | −0.23 | −0.40, −0.06 | <0.05
| | | | | | 3992 | nd | | nd
| | | | | | BMI ≥35 2621 | nd | | nd | | −0.17 | −0.38, +0.04 | NS
| | | | | | 2539 | nd | | nd
| | | | | | | | | | | Overall (interaction), BMI | | 0.04
17502530 | Caan 2007 | Weight | Kg | Ca+D | 7 yr | Base Ca <1200/d 10819 | nd | | nd | | −0.19 | −0.29, −0.09 | <0.05
17502530 | Caan 2007 | Weight | Kg | Placebo | | 10658 | nd | | nd
| | | | | | Base Ca ≥1200 7002 | nd | | nd | | −0.05 | −0.17, +0.08 | NS
| | | | | | 7095 | nd | | nd
| | | | | | | | | | | Overall (interaction), BASE CA INTAKE | | 0.09

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
17502530 | Caan 2007 | RCT | Yes | Yes | NA | Yes | Yes | Yes | Yes | Yes | Yes | B
Adverse Event(s): ** | | | | | | Women with intolerable GI symptoms were treated by reducing the number of times per day or days per week that study medication was taken w/o unblinding participant or study staff. No other data on AEs provided.
Explanation for Overall Quality Grade (if not Grade A): | | | | | | It was the consensus among the Tufts EPC that overall, the methodological quality of the trial was B, particularly when the trial is being used to guide decisions about DRI, as opposed to decisions about whether to actively recommend supplementation for an individual woman.

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT–Parallel, RCT–Cross-over, RCT–Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Chan 2001

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
11566656 | Chan 2001 | Cohort | Male physicians, subjects who returned the dietary questionnaires, did not have a diagnosis of cancer at baseline, and provided information on body mass index | nd | 1995 | Physician’s Health Study | The CaP Cure Young Investigator Award (JMC) and National Institutes of Health | JHL/SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location(e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake…etc.)
11566656 | Chan 2001 | Cohort | US | 22071 | 20885 | 53.3 | nd | 100 | nd | BMI=24.9 | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed information as possible on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
11566656 | Chan 2001 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | nd | nd | nd | nd | Nd
11566656 | Chan 2001 | Dietary calcium intake | Short self- administered questionnaire | Database from the prospective Health Professional Follow-up Study | nd | nd | nd | | nd | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
11566656 | Chan 2001 | Secondary | Prostate cancer | Requested permission to obtain hospital records and pathology reports for review by the study investigators. Information on tumor grade and stage at diagnosis was extracted, and the diagnosis of prostate cancer was confirmed by medical chart review in 99% of cases.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
11566656 | Chan 2001 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
11566656 | Chan 2001 | Demographics (e.g., age, gender, race, education)? | Yes * - Age
11566656 | Chan 2001 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes * - BMI
11566656 | Chan 2001 | Medical conditions
11566656 | Chan 2001 | Medication
11566656 | Chan 2001 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
11566656 | Chan 2001 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes * - Smoking, exercise
11566656 | Chan 2001 | Other | Randomized treatment in the original trial (aspirin, β- carotene, or placebo), food score

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | MeanCa level/dose | No. of Cases (Event) * | No. of Non-cases/Total N ** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI ** | P between groups *** | P for trend ****
11566656 | Chan 2001 | Prostate cancer | Dairy calcium intake Group 1 | | 0–150 | 155 | | 132 | Adjusted | RR | 1.00 | | | 0.05
| | | Group 2 | | 151–300 | 206 | | 132 | Adjusted | RR | 1.21 | 0.96–1.53
| | | Group 3 | | 301–600 | 377 | | 132 | Adjusted | RR | 1.35 | 1.09–1.66
| | | Group 4 | | > 600 | 274 | | 132 | Adjusted | RR | 1.29 | 1.04–1.62

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
11566656 | Chan 2001 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | Nd | a) Method reported? (y/n) | y | a) One of the prespecified methods *** was used? (y/n) | N | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | y | a) Prospective collection of data? (y/n) | Y
11566656 | Chan 2001 | b) Sampling of population random or consecutive? (y/n) | nd | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | n | Time from sample collection to sample analysis reported? (y/n) | NA | | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
11566656 | Chan 2001 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | n
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): . | | | | | | | Post-hoc analysis of RCT (but, we categorized this as a cohort study because the treatment in the original trial was not Ca), Dietary assessment method was not validated.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Chebowski 2008

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
19001601 | Chebowski 2008 | RCT Case- cohort study | Post menopausal enrolled in WHI trial of hormonal therapy and dietary modification. Aged 50–79 y and life expectancy of >3y, no prior breast cancer, and no other cancers within 10 y | Women with h/o hypercalcemia, kidney stones, corticosteroid or calcitriol use | Until March 2005 | WHI | Gov | GR

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
19001601 | Chebowski 2008 | RCT Case- cohort study | US 38 N | 68.132 | 36,282 | ND | 50–79 | 0 | CaD: White 82.8% Black 9.3% 4.3% American Indian 0.4% Asian pacific Islander 2.0% Unknown 1.2% Placebo: White 83.4% Black 9% Hispanic 4% American Indian 0.4% Asian pacific Islander 2.0% Unknown 1.2% | CaD <25 26.2% 25-<30 35.8% ≥ 30 38% Placebo <25 26.8% 25-<30 36.0% ≥ 30 37.2% | CaD : Alcohol use in Non drinker 10.3% Past drinker 17.7% Current drinker 72% Smoking: Never smoked 52% Past smoker 40.3% Current smoker 7.8% | Baseline vitD supplementation: CaD arm Yes: 47.1% No: 52.9% Placebo arm Yes 47. 6% No 52.4% Baseline Ca supplementation: CaD arm <800: 34.3% 800-<1200: 26.5% ≥1200: 39.3% Placebo arm <800: 33.8% 800-<1200: 26.2% ≥1200: 40.0%

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed information as possible on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
19001601 | Chebowski 2008 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | DiaSorin Liason Chemiluminescent immunoassay | Y 11.8% | ND | ND | Equal % of subjects in both arms were taking vitamin D
19001601 | Chebowski 2008 | Dietary calcium intake | Modified block FFQ | ND | N | NA | NA | | ND | the % of subjects in the placebo arm who were getting Ca were higher for the highest level ≥1200

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
19001601 | Chebowski 2008 | Calcium carbonate Vit D3 | GlaxoSmith Kline | 400 IU vit D 1000 mg Ca | 7 years | 200 IU vit D x twice daily 500 mg Ca x twice daily
Co-intervention(s) * : | | | Hormone use was similar in both arms. CaD arm: Tamoxifen use 0.08%; raloxifene use 0.10% Placebo arm: Tamoxifen use 0.06%; raloxifene use 0.11%
Compliance/Adherence: | | | 60%–63% during first 3 years of follow-up

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
19001601 | Chebowski 2008 | Not clear. Most likely secondary outcome | Incident invasive breast cancer | Confirmed by both local and central medical record and pathology report review by trained adjudicators. Tumor characteristics were coded by SEER program guidelines.

UI | Author Year | Comments
19001601 | Chebowski 2008 | The trial is unable to discern the independent effects of Ca and Vit D, since the use of supplementation is the same in both arms.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

[underlined: This sections is only applicable for the nested case-control study of Vitamin D biomarker section]

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
19001601 | Chebowski 2008 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Both arms liberally used Ca D supplements
19001601 | Chebowski 2008 | Demographics (e.g., age, gender, race, education)? | Yes
19001601 | Chebowski 2008 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes
19001601 | Chebowski 2008 | Medical conditions
19001601 | Chebowski 2008 | Medication | Hormonal therapy, estrogen alone or combined with progestin
19001601 | Chebowski 2008 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | Latitude of the clinical center
19001601 | Chebowski 2008 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes
19001601 | Chebowski 2008 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

(This is from RCT part of the study)

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | Result | 95% CI | P btw
19001601 | Chebowski 2008 | Total breast cancer | Calcium carbonate 400 IU Vit D3 1000 mg | 7 y | 668 | 18176 | HR | 0.96 | 0.86 to 1.07 | NS
19001601 | Chebowski 2008 | Total breast cancer | Placebo | | 693 | 18106 | HR | 0.96 | 0.86 to 1.07 | NS
| | Death from breast cancer | Calcium carbonate 400 IU Vit D3 1000 mg | 7 y | 23 | 18176 | HR | 0.99 | 0.55 to 1.76 | NS
| | Death from breast cancer | Placebo | | 23 | 18106

* Example: OR Ca/placebo

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

(This section is from the nested case-control study that examined pre-randomization levels were associated with breast cancer)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level | Mean Ca level/dose | No. of Cases (Event) * | Total N ** | Mean Follow-up, mo | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups *** | P for trend ****
19001601 | Chebowski 2008 | Invasive breast cancer | ≥67.6 Q1 Baseline 25(OH)D | 81.9 (13.2) | | CaD 86 Pl 76 | 195 | 7 y | Adj | OR | 0.89 | 0.58 to 1.36 | | 0.2 (main effect)
| | | 55.4≤ 67.6 Q2 Baseline 25(OH)D | 60.9 (3.5) | | CaD 95 Pl 86 | 185 | 7 y | Adj | OR | 1.25 | 0.83 to 1.90
| | | 43.9≤55.4 Q3 Baseline 25(OH)D | 49.2 (3.3) | | CaD 102 Pl 92 | 171 | 7 y | Adj | OR | 1.07 | 0.70 to 1.62
| | | 32.4≤43.9 Q4 Baseline 25(OH)D | 38.5 (3.3) | | CaD 71 Pl 102 | 171 | 7 y | Adj | OR | 0.69 | 0.45 to 1.06
| | | <32.4 Q5 Baseline 25(OH)D | 23.6 (5.9) | | CaD 94 Pl 91 | 176 | 7 y | Adj | OR | 0.91 | 0.60 to 1.39

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
19001601 | Chebowski 2008 | RCT-Parallel | | y | n | y | nd | y | y | y | y | B
Adverse Event(s): ** | | | | | | ND (patients were excluded if they had kidney stones, etc.)
Explanation for Overall Quality Grade (if not Grade A): | | | | | | It was the consensus among the Tufts EPC that overall, the methodological quality of the trial was B, particularly when the trial is being used to guide decisions about DRI, as opposed to decisions about whether to actively recommend supplementation for an individual woman.

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse events.

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
19001601 | Chebowski 2008 | a) Eligibility criteria clear? (y/n) | y | a) Exposure assessor blinded to outcome info? (y/n) | n | a) Method reported? (y/n) | y | a) One of the prespecified methods *** was used? (y/n) | y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | a) Clear definition of outcome, including time of ascertainment? (y/n) | y | a) Prospective collection of data? (y/n) | y
19001601 | Chebowski 2008 | b) Sampling of population random or consecutive? (y/n) | y | b) Outcome assessor blinded to exposure measurement? (y/n) | n | b) Food composition database or suppl composition reported? (y/n) | n | Time from sample collection to sample analysis reported? (y/n) | n | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | y | b) Loss to follow-up <20%? (y/n) | y | b) Analysis was planned when cohort was formed? (y/n) | n
19001601 | Chebowski 2008 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | y | | | | | b) Justification of final adjusted model selection? (y/n) | y | c) Do the authors specify a primary outcome? (y/n) | n | c) ustification of sample size (includes sample size calculations)? (y/n) | na
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Time from sample collection to analysis not reported, unclear how the effect of VitD was delineated when both arms had vitD intake at baseline.

* Check “NA”and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Chel 2008

^ 1 ^ ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17874029 | Chel 2008 | RCT | Nursing home residents | outside sunshine >1/wk; vit D or Ca supplement; >1 vit D-fortified food or drink; completely immobilized; poor life expectancy | nd | nd | Solvay Pharm. provided meds; ZonMw (the Netherlands Org for Health Research & Development | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
17874029 | Chel 2008 | RCT | The Netherlands, 52° N | 338 | 338 | 84 (6) | nd | 22 | nd | nd | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed information as possible on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
17874029 | Chel 2008 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | RIA (Diasorin) | y; interassay CV 10% at 30 nmol/L | nd | nd | 100 IU/d vit D from food
| | Dietary calcium intake

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
17874029 | Chel 2008 | vit D3 600 IU/d vs. placebo | Solvay | | 4.5 mo | 1 tab
| | vit D3 4200 IU/wk vs. placebo | Solvay | | 4.5 mo | 7 tabs once a wk
| | vit D3 18,000 IU/mo vs. placebo | Solvay | | 4.5 mo | one powder once a month
Co-intervention(s) * :
Compliance/Adherence: | | | 276/338 completed the 4 mo study; compliance with meds ~80% in a random sample of 96/338 participants

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17874029 | Chel 2008 | primary | 25(OH)D concentration

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder(including matching factors) | Specific comments for confounders
17874029 | Chel 2008 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
17874029 | Chel 2008 | Demographics (e.g., age, gender, race, education)? | no *
17874029 | Chel 2008 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no *
17874029 | Chel 2008 | Medical conditions | no
17874029 | Chel 2008 | Medication | no
17874029 | Chel 2008 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
17874029 | Chel 2008 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no *
17874029 | Chel 2008 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline SD * | Final ** | Final SD * | Net difference | Net difference CI | P between
17874029 | Chel 2008 | increase in 25(Oh)D | nmol/L | Any vit D supplement | 4 mo | 139 | | | | | 38.5 | 35.7–41.3 | 0.000
17874029 | Chel 2008 | increase in 25(Oh)D | nmol/L | Placebo | 4 mo
| | | | 600 IU daily | 4 mo | 46 | 23.0 | 8.3 | 69.9 | 17.8 | 47.2 | 42.3–52.1 | 0.000
| | | | Placebo daily | 4 mo | 45 | 25.2 | 12.1 | 25.5 | 12.0
| | | | 4200 IU 1x/wk | 4 mo | 48 | | | | | 40.7 | 35.8–45.6 | 0.000
| | | | Placebo weekly | 4 mo | 44
| | | | 18,000 IU 1x/mo | 4 mo | 45 | | | | | 27.6 | 22.8–32.5 | 0.000
| | | | Placebo monthly | 4 mo | 48
| | | | 600 IU daily | 4 mo | 46 | | | | | 6.6 | 1.7–11.4 | 0.009
| | | | 4200 IU 1x/wk | 4 mo | 48
| | | | 4200 IU 1x/wk | 4 mo | 48 | | | | | 11.2 | 6.3–16.1 | 0.000
| | | | 18,000 IU 1x/mo | 4 mo | 45
| | | | 18,000 IU 1x/mo | 4 mo | 45 | | | | | −17.8 | −22.7– −12.8 | 0.000
| | | | 600 IU daily | 4 mo | 46

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Comments for Results
17874029 | Chel 2008 | Figure 2 in paper does not seem to agree with results in Table 2.

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
17874029 | Chel 2008 | RCT | y | n | NA | y | nd | n | y | y | y | B
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Compliance assessed in a random sample of 96/338 participants; baseline medical conditions not reported; 12% of participants died during study period (number not stratified between placebo and active intervention)

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse events.

## Cheng 2005

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
16280447 | Cheng 2005 | RCT | 10–12 y old girls; Tanner 1 to 2; dietary calcium <900 mg/d | serious medical conditions; medications that affect bone metabolism; | nd | nd | government and industry | SI

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
16280447 | Cheng 2005 | RCT | Jyvaskyla, Finland 62°24′N | 195 | 165 | 11.2 | 10–12 | 0 | nd | BMI: 18.2 | no serious medical conditions | dietary calcium: 670 mg/d; vit D 2.5 μg/d

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
16280447 | Cheng 2005 | 25(OH)D | | | | enzyme immunoassay (Immunodiagnostic Systems Ltd, UK) | y; intra and interassay CV: 4.2%, 6.1% | nd | baseline: Dec to Feb | vit D 2.5 μg/d
| | Dietary calcium intake | FFQ x 3 d | nd | n | NA | NA | | | dietary calcium: 670 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
16280447 | Cheng 2005 | Calcium and vit D | Tums or Kalcipos (calcium); Deetipat (vit D3) | 1000 mg calcium carbonate + 200 IU (5 μg) vit D3/d | 24 mo | one tab in am; one tab in pm; drops in am
| | Calcium and placebo | Tums or Kalcipos (calcium) | 1000 mg calcium carbonate + vit D placebo | | one tab in am; one tab in pm; drops in am
| | dairy product | | 1000 mg calcium equivalent
| | placebo | | calcium placebo + vit D placebo | | one tab in am; one tab in pm; drops in am
Co-intervention(s) * : | | | none
Compliance/Adherence: | | | 126 completed intervention with >50% compliance

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
16280447 | Cheng 2005 | primary | bone indexes | by dual-energy X-ray absorptiometry

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
16280447 | Cheng 2005 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
16280447 | Cheng 2005 | Demographics (e.g., age, gender, race, education)? | Yes * | age
16280447 | Cheng 2005 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes * | BMI; Tanner stage
16280447 | Cheng 2005 | Medical conditions
16280447 | Cheng 2005 | Medication
16280447 | Cheng 2005 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
16280447 | Cheng 2005 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes * | physical activity
16280447 | Cheng 2005 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure Category/Intervention Group | Crude or Adjusted analysis? | Mean Follow-up (months) | No. Analyzed | Baseline | Baseline CI/SE/SD * | Delta ** | Delta SD * | Net difference *** | Net difference CI/SE/SD * | P between groups ***
16280447 | Cheng 2005 | change in BMC (ITT analysis) | g | Calcium and vit D3 | adj | 24 mo | 46 | 1328 | 292 | 34.7% | 1.3% | | | NS
| | | | Calcium and placebo | | | 41 | 1431 | 274 | 35% | 1.4%
| | | | dairy product | | | 39 | 1343 | 235 | 38.1% | 1.4%
| | | | placebo | | | 39 | 1383 | 257 | 35% | 1.4%
| | areal BMD | g/cm2 | Calcium and vit D3 | adj | 24 mo | 46 | 0.934 | 0.1 | 9.8% | 0.5% | | | aBMD increased more in the dairy group with compliance>50% than in placebo (P=0.044)
| | | | Calcium and placebo | | | 41 | 0.945 | 0.1 | 9.7% | 0.5%
| | | | dairy product | | | 39 | 0.935 | 0.1 | 10.4% | 0.5%
| | | | placebo | | | 39 | 0.939 | 0.1 | 8.9% | 0.5%

Duplicate one row per exposure category or intervention group. Please write “nd” if there was no data reported. DO NOT LEAVE BLANK.

* Please choose one and delete the others

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

OTHER RESULTS

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
16280447 | Cheng 2005 | | With the use of hierarchical linear model to control for growth velocity; differences in BMD between dairy and placebo disappeared.
16280447 | Cheng 2005 | other bone indices | see Table 3 in paper for other bone indices

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
16280447 | Cheng 2005 | RCT | y | nd | NA | y | y | y | y | y | y | C
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | small sample size in each group. Underpowered and compliance was low.

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Cifuentes 2004

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
15213038 | Cifuentes 2004 | RCT | Weight-stable, overweight, post-menopausal women | Women with disease states, including osteoporosis, and those using medication known to influence calcium or bone metabolism. | 2000–2003 | Nd | NIH | KP

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
15213038 | Cifuentes 2004 | RCT | New Brunswick, NJ, USA 40.486° | 73 | 57 | 61(5) | 52–75 | 0% | Nd | BMI: 26.9(1.9) | Nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
15213038 | Cifuentes 2004 | 25(OH)D and 1,25(OH) _ 2 _ D | | | | RIA | N | Nd | April and October | 25(OH)D Nl Ca/Wt maint: 84.1 nmol/L Nl Ca/Wt loss: 73.3 High Ca/Wt maint: 68.9 High Ca/Wt loss: 61.6 Sig difference among groups
| | Dietary calcium intake | 3 day diet record (at baseline and after 6 weeks) | Nd | N | Nd | Nd | | Nd | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
15213038 | Cifuentes 2004 | Calcium | Supplement of calcium citrate, Mission Pharmacal, San Antonio, TX | 1.2 g/d in high calcium group | 6 weeks | 2 Ca tablets in the morning, 3 in the evening
| | Placebo | Supplement of calcium citrate, Mission Pharmacal, San Antonio, TX | 0.4 g/d in normal calcium group | 6 weeks | 2 tablets in the morning, 3 in the evening (4 placebo tablets and 1 calcium tablet)
Co-intervention(s) * : | | | Weight loss group (targeted loss of ≥ 2.5% of bodyweight), weight maintenance group. Each group was split into high calcium and normal calcium groups.
Compliance/Adherence: | | | nd

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
15213038 | Cifuentes 2004 | Primary | Weight change | Change in weight in kg
| | Secondary | Curve 4-Ca→25(OH)D | Change in 25(OH)D after 6 weeks of calcium intervention vs placebo

UI | Author Year | Comments
| | NS but substantial differences (in small number of participants) in baseline weight

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
15213038 | Cifuentes 2004 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
15213038 | Cifuentes 2004 | Demographics (e.g., age, gender, race, education)? | Yes | age
15213038 | Cifuentes 2004 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | Baseline body weight
15213038 | Cifuentes 2004 | Medical conditions
15213038 | Cifuentes 2004 | Medication
15213038 | Cifuentes 2004 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | Season of blood sample collection
15213038 | Cifuentes 2004 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | No
15213038 | Cifuentes 2004 | Other | Year of recruitment, estrone, sNTx

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure/Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Baseline SD * | Final | Final | Net difference | Net difference CI/SE/SD * | P between
15213038 | Cifuentes 2004 | Body weight | Kg | Calcium, both weight maintenance (WM) and weight loss (WL) groups | 6 weeks | 10 16 | 70.9 71.5 | 5.1 5.8 | 70.9 67.9 | 5.5 5.7 | 0.9 | nd | 0.3227
15213038 | Cifuentes 2004 | Body weight | Kg | Placebo, both weight maintenance (WM) and weight loss (WL) groups | 6 weeks | 15 16 | 68.0 74.5 | 7.7 7.3 | 68.4 71.2 | 7.5 7.1
| | 25(OH)D | nmol/L | Calcium, both weight maintenance (WM) and weight loss (WL) groups | 6 weeks | 10 16 | 81.4 74.1 | 14.6 22.0 | 80.1 76.9 | 16.2 18.2 | 1.5 | Nd | 0.1639
| | 25(OH)D | nmol/L | Placebo, both weight maintenance (WM) and weight loss (WL) groups | 6 weeks | 15 16 | 96.6 85.8 | 19.9 21.9 | 98.4 94.6 | 26.0 27.7
| | 1,25(OH)D | pmol/L | Calcium, both weight maintenance (WM) and weight loss (WL) groups | 6 weeks | 10 16 | 117.0 102.3 | 34.0 32.4 | 116.9 113.8 | 29.8 36.2 | 11.4 | nd | 0.9663
| | 1,25(OH)D | pmol/L | Placebo, both weight maintenance (WM) and weight loss (WL) groups | 6 weeks | 15 16 | 92.9 135.8 | 42.9 41.4 | 99.4 145.2 | 35.0 41.3

Baseline=baseline value; Final=final value; Delta=change value from baseline, which is Final-Baseline value; Net difference=differences in deltas

* Enter outcome metric reported in the unadjusted or adjusted result section

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
15213038 | Cifuentes 2004 | RCT-parallel | Y | nd | Y | N | Y | nd | Mostly | Y | Y | B
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | No mention of intention-to-treat or compliance rate, high dropout rate. Questionable statistics.
Comment | | | | | | Really 2 separate trials. Combining wt maintenance and wt loss in statistical test is of questionable value. However, they did control for various factors, including the substantial differences in baseline weights. However, the very small number of subjects may have precluded meaningful adjustment (of 6 variables)

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Colditz 1992

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
13151203 | Colditz 1992 | Cohort study | -participant of Nurses’ Health Study -female | - ≥10 food items blank on 1980 dietary questionnaire - Implausibly high or low score for total food intake on 1980 dietary questionnaire -hx of DM, CHD, or cancer before the return of the 1980 questionnaire | 1976–1986 | Nurses’ Health Study | NIH | MB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
13151203 | Colditz 1992 | Cohort study | various | 98464 | 84360 | nd | nd (NHS participants 30–55 yrs) | 0% | Predominantly white | nd | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
13151203 | Colditz 1992 | 25(OH)D and/or 1,25(OH) _ 2 _ D
| | Dietary calcium intake | SFFQ | nd | nd | nd | nd | | nd | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson’s food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
13151203 | Colditz 1992 | nd | NIDDM | Report of one of the following: 1. at least one classical symptom (wt loss, hunger, thirst, polyuria, or pruritis) plus a plasma fasting glucose concentration ≥ 7.77 mmol/L or a random plasma glucose ≥ 11.10 mmol/L, or 2.at least two elevated plasma glucose concentrations ≥ 11.10 mmol/L in the absence of symptoms.

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
13151203 | Colditz 1992 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake
13151203 | Colditz 1992 | Demographics (e.g., age, gender, race, education)? | Yes | Controlled for age
13151203 | Colditz 1992 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | Controlled for BMI
13151203 | Colditz 1992 | Medical conditions
13151203 | Colditz 1992 | Medication
13151203 | Colditz 1992 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
13151203 | Colditz 1992 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | Controlled for EtOH consumption
13151203 | Colditz 1992 | Other | | Also adjusted for family hx of DM, prior wt change, and time period.

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non-cases/Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups *** | P for trend ****
13151203 | Colditz 1992 | NIDDM in BMI < 29 participants | Quintile 1 | | | | | Adjusted | RR | 1.0
| | | Quintile 2 | | | | | Adjusted | RR | 1.16
| | | Quintile 3 | | | | | Adjusted | RR | 0.67
| | | Quintile 4 | | | | | Adjusted | RR | 0.69
| | | Quintile 5 | | | | | Adjusted | RR | 0.70 | 0.47–1.04 | P>0.05 (Q1 vs. Q5) | 0.005

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event) * | No. of Non-cases/Total N ** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups *** | P for trend ****
13151203 | Colditz 1992 | NIDDM in BMI ≥ 29 participants | Quintile 1 | | | | | Adjusted | RR | 1.0
| | | Quintile 2 | | | | | Adjusted | RR | 0.95
| | | Quintile 3 | | | | | Adjusted | RR | 0.92
| | | Quintile 4 | | | | | Adjusted | RR | 0.91
| | | Quintile 5 | | | | | Adjusted | RR | 0.84 | 0.59–1.18 | P>0.05 (Q1 vs. Q5) | 0.26

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Vit D level/dose | Mean Ca level/dose | No. of Cases (Event)* | No. of Non-cases/Total N** | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups*** | P for trend****
13151203 | Colditz 1992 | NIDDM in BMI < 29 participants | Quintile 1 | | | | | Adjusted for same as above in addition to Mg and K | RR | 1.0
| | | Quintile 2 | | | | | | RR | 1.19
| | | Quintile 3 | | | | | | RR | 0.71
| | | Quintile 4 | | | | | | RR | 0.77
| | | Quintile 5 | | | | | | RR | 0.85 | 0.53–1.37 | P>0.05 (Q1 vs. Q5)

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
13151203 | Colditz 1992 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | Y | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | N | a) Adjusted or matched for ANY confounder s (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment ? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
13151203 | Colditz 1992 | b) Sampling of population random or consecutive ? (y/n) | N | b) Outcome assessor blinded to exposure measurement ? (y/n) | Y | b) Food composition database or suppl composition reported? (y/n) | N | Time from sample collection to sample analysis reported ? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | N | a) Adjusted or matched for ANY confounder s (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
13151203 | Colditz 1992 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | N | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | N | c) Justification of sample size (includes sample size calculations) ? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | B
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | No Ca ranges given for quintiles. Food composition database that was used was not reported.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Corder 1993

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
8220092 | Corder 1993 | Case-cohort study | Ambulatory, generally healthy in 1964–1971. Sera stored. Stayed as a Kaiser member. Cases: Diagnosed with prostate cancer before 1988. Blacks oversampled (for power). Controls: Alive without prostate cancer at time of (matched) case diagnosis. Matched for race, age±3 yr, initial screening±3 day of year (to account for possible seasonal variation) | “Orientals” excluded (for power). Prostate cancer not confirmed. Missing sera. | Vit D screening 1964–71 Cancer diagnosis <1988 | (Kaiser Permanente) | NCI National MS Society | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat …etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake …etc.)
8220092 | Corder 1993 | Case-cohort study | San Francisco Bay area, US 37° 46′ | 200 cases 200 controls | 181 cases 181 controls | 57 (nd) | 38–81 | 100 | Black 91 pairs White 90 pairs | nd | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Background exposure data
8220092 | Corder 1993 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | Competitive protein binding (Haddad 1971) 25-D Do not distinguish between D2 and D3 | no | Mean 11.5 years to diagnosis (range 1–23 yr) | 25(OH)D: 15–80 ng/ml 1,25(OH) _ 2 _ D: 19–50 pg/ml
| | Dietary calcium intake

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
8220092 | Corder 1993 | Primary | Prostate cancer diagnosis | Invasive adenocarcinoma by histopathology
8220092 | Corder 1993 | Secondary | Prostate cancer stage | Gleason grade
8220092 | Corder 1993 | Secondary | Prostate cancer death | Death record

UI | Author Year | Comments
8220092 | Corder 1993 | “To avoid exclusion of all 19 controls [matched to 19 excluded cases] and 6 cases paired to excluded cases and controls, 6 case-control pairs were salvaged from their respective pair members by forming the best age and race matches.”

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
8220092 | Corder 1993 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | No
8220092 | Corder 1993 | Demographics (e.g., age, gender, race, education)? | Yes | Race (matched), age (matched)
8220092 | Corder 1993 | Anthropometrics (e.g., BMI, body weight, % body fat)? | No
8220092 | Corder 1993 | Medical conditions | No
8220092 | Corder 1993 | Medication | No
8220092 | Corder 1993 | Sunlight exposure and its proxy variables (e.g., physical activity level, occupation, sun exposure, location) | Yes | Day of year (matched)
8220092 | Corder 1993 | Smoking and other life styles variables | No
8220092 | Corder 1993 | Other | No

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

OTHER RESULTS, Part 1

ONLY USE THE FOLLOWING BOX WHEN THE TYPE OF RESULT DATA DO NOT FIT THE TABLES PROVIDED ABOVE

UI | Author Year | Outcome | Results
8220092 | Corder 1993 | Prostate cancer | “A separate model for men less than 57 years of age was not predictive of risk.”
| | | “In a conditional logistic model, the measured values of 25-D, 1,25-D, and their interaction were jointly predictive of the risk of prostate cancer (P=.02)”
| | | “Risk in relation to vitamin D metabolite levels depended on age at serum storage (P=.002) and age at case diagnosis (P=.05).”
| | | “Pattern of risk was similar in black and white men (P=0.51).”
| | Palpable tumor (n=56) & Gleason Grade 7–10 (n=44) | Detailed OR data for these 2 outcomes for men ≥57 years: Higher quartiles of both 25-D and 1,25-D were protective
| | Prostate cancer death (n=51) | Vitamin D metabolite levels unrelated to risk of prostate cancer death overall and in subgroups by age.

The odds [ratio] of prostate cancer for eqch quartile of 25-D and 1,25-D compared to their lowest quartiles.

All men. N=181 pairs (Unadjusted for other variables, implied)

| Quartile of 1,25-D (pg/mL)
Quartile of 25-D (ng/mL) | 1 (5–26) | 2 (27–32) | 3 (33–39) | 4 (40–81)
1 (3–18) | 1.00 | 0.53 P<.05 | 0.28 P<.05 | 0.15 P<.05
2 (19–23) | 0.96 | 0.58 | 0.35 | 0.21
3 (24–28) | 0.93 | 0.63 | 0.43 | 0.29
4 (29–52) | 0.90 | 0.69 | 0.53 | 0.41

The odds [ratio] of prostate cancer for eqch quartile of 25-D and 1,25-D compared to their lowest quartiles.

Men ≥ 57 years old at baseline. N=91 pairs (57 is median age; 30 black, 61 white) (Unadjusted for other variables, implied)

| Quartile of 1,25-D (pg/mL)
Quartile of 25-D (ng/mL) | 1 (5–26) | 2 (27–32) | 3 (33–39) | 4 (40–81)
1 (3–18) | 1.00 | 0.22 P<.05 | 0.05 P<.05 | 0.01 P<.05
2 (19–23) | 0.79 | 0.23 | 0.07 P<.05 | 0.02 P<.05
3 (24–28) | 0.62 | 0.24 | 0.09 | 0.03 P<.05
4 (29–52) | 0.48 | 0.24 | 0.12 | 0.06

P=.0001 by (unadjusted) logistic regression (P=.98 for men<57 at serum storage).

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
8220092 | Corder 1993 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | Y | a) Method reported? (y/n) | NA | a) One of the prespecified methods *** was used? (y/n) | No | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
8220092 | Corder 1993 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | NA | Time from sample collection to sample analysis reported? (y/n) | Y | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for categorical analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | N
8220092 | Corder 1993 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | NA | | | | | b) Justification of final adjusted model selection? (y/n) | Y | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Vit D measured with competitive protein binding and calf thymus receptor assays. Inadequate adjustment.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Duris 1996

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
8682453 | Duris 1996 | Other intervention study | Patients with adenomatous polyps after polypectomy receiving calcium chemoprevention (n=175) and patients with adenomatous polyps after polypectomy who did not receive calcium chemoprevention (n=9) Patients with colorectal cancer after surgery receiving calcium chemoprevention and patients with colorectal cancer after surgery who did not receive calcium chemoprevention | nd | Group with polyps: nd Patients with colorectal cancer after surgery receiving calcium chemoprevention (Group C): 1992 Patients with colorectal cancer after surgery who did not receive calcium chemoprevention (Group A): 1984; Group B): 1985 | nd | nd | AT

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weigh t, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
8682453 | Duris 1996 | Other intervention study | Bratislava, Slovak Republic (48° 40′ 0″ N) | Patients with polyps and calcium, n=175 Patients with polyps without calcium, n=9 Patients with CRC and calcium, n=50 Patients with CRC without calcium (Group A, 1984 year), n=46 Patients with CRC without calcium (Group B, 1985 year), n=47 | Patients with polyps and calcium, n=175 Patients with polyps without calcium, n=9 Patients with CRC and calcium, n=50 Patients with CRC without calcium (Group A, 1984 year), n=46 Patients with CRC without calcium (Group B, 1985 year), n=47 | Patients with polyps and calcium: 55 yr Patients with polyps without calcium: 48.7 yr For CRC group: nd | Patients with polyps and calcium, range: 38–75 Patients with polyps without calcium, range: 30–69 For CRC group: nd | Patients with polyps and calcium: 61.7% Patients with polyps without calcium: 66.7% For CRC group: nd | nd | nd | Patients with history of polyps, n=184 Patients with history of CRC, n=143 | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
8682453 | Duris 1996 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | na | na | na | na | na
8682453 | Duris 1996 | Dietary calcium intake | nd | nd | nd | nd | nd | | nd | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
8682453 | Duris 1996 | Caclium (patients with polyps) | Calcium carbonicum | 2 g | Mean: 3.1 yr range 1–6 yr (based on follow up period) | nd
8682453 | Duris 1996 | Caclium (patients with CRC) | Calcium carbonicum (implied) | nd | ~50 mo (based on Kaplan Meier figure for survival) | nd
Co-intervention(s) * : nd
Compliance/Adherence: nd

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
8682453 | Duris 1996 | nd | Adenomas recurrence | nd (only for patients with history of polyps)
8682453 | Duris 1996 | nd | Survival | nd (only for patients with CRC history)

UI | Author Year | Comments
8682453 | Duris 1996 | This publication includes two separate groups of patients who were analyzed separately; therefore, it could be considered as two different studies reported in the same publication (first study on patients with adenomatous polyps after polypectomy; second study on patients with CRC after surgery) Although the %patients with adenomatous recurrence is based on the initial number of patients, the article reports that 5 patients died and 6 additional patients did not attend examination visits

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
8682453 | Duris 1996 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | no
8682453 | Duris 1996 | Demographics (e.g., age, gender, race, education)? | no
8682453 | Duris 1996 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no
8682453 | Duris 1996 | Medical conditions | no
8682453 | Duris 1996 | Medication | no
8682453 | Duris 1996 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | no
8682453 | Duris 1996 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no
8682453 | Duris 1996 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | Result | 95% CI | P btw
8682453 | Duris 1996 | Adenomas recurrence | Calcium carbonicum, 2g/day | 37.2 | 12 | 175 | nd | nd | nd | nd | nd | nd | nd
8682453 | Duris 1996 | Adenomas recurrence | No chemoprevention | 36 | 5 | 9 | nd | nd | nd | nd | nd | nd | nd
| | Survival | Calcium carbonicum (implied) | nd | nd | 50 | nd | nd | nd | 0.048 | nd | nd | nd
| | Survival | No chemoprevention (Group B: patients from 1985) | nd | nd | 47 | nd | nd | nd | 0.048 | nd | nd | nd
| | Survival | Calcium carbonicum (implied) | nd | nd | 50 | nd | nd | nd | nd | nd | nd | nd
| | Survival | No chemoprevention (Group C: patients form 1984) | nd | nd | 46 | nd | nd | nd | nd | nd | nd | nd

* Example: OR Ca/placeb

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
8682453 | Duris 1996 | Case series | NA | NA | NA | y | nd | y | n | n | n | C
Adverse Event(s): ** | | | | | | nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Study design has no validity to test the hypothesis implied. Authors seem to have two case series (one with polyps and another one with CRC) and they use calcium chemoprevention to two subgroups (one subgroup with polyps and another with CRC). The comparison between those who received calcium with those patients without calcium does not turn this case series study to a case control or case cohort study. A lot of information on the concept, the research questions, population recruited, and the results are not reported.

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## Dwyer 1996

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
8890661 | Dwyer 1996 | Cohort Study | NHANES I 25–74 yo White or black. Sufficient data | HTN at baseline | 1971–75 | NHANES I | nd | EB

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat...cetc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake...etc.)
8890661 | Dwyer 1996 | Cohort Study | US, various | 6634 | 6634 | 46 (~14) | 25–74 | 63% | White 86% Black 14% | BMI 25.4 | No HTN | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
| | 25(OH)D and/or 1,25(OH) _ 2 _ D
8890661 | Dwyer 1996 | Dietary calcium intake | 24 hour recall | nd | nd | NA | NA | | NA | nd

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
8890661 | Dwyer 1996 | 1° | Incident HTN | HTN medication prescribed
| | 2° | Incident HTN | SBP ≥ 160 or ≥ DBP 95 or medication prescribed

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
8890661 | Dwyer 1996 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes | Calories
8890661 | Dwyer 1996 | Demographics (e.g., age, gender, race, education)? | Yes | Age, Sex, Race
8890661 | Dwyer 1996 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes | BMI
8890661 | Dwyer 1996 | Medical conditions
8890661 | Dwyer 1996 | Medication
8890661 | Dwyer 1996 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
8890661 | Dwyer 1996 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | Yes | EtOH
8890661 | Dwyer 1996 | Other

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison * | Result | 95% CI | P btw | Result | 95% CI | P btw
8890661 | Dwyer 1996 | HTN (Rx) | Calcium intake, per 1 g/day increase | 10 year | 1704 | 6634 | OR (increase in Ca intake) | | | | 0.90 | 0.77, 1.04 | NS
8890661 | Dwyer 1996 | HTN (Rx) | | | | | OR (increase in Ca intake) | | | | 0.90 | 0.77, 1.04 | NS
| | HTN (BP or Rx) | Calcium intake, per 1 g/day increase | 10 year | 1222 | 5527 | OR (increase in Ca intake) | | | | 0.99 | 0.85, 1.172 | NS
| | HTN (BP or Rx) | | | | | OR (increase in Ca intake) | | | | 0.99 | 0.85, 1.172 | NS

* Example: OR Ca/placebo

≥2 ARMS/GROUPS: DICHOTOMOUS OUTCOMES (e.g. OR, RR, %death)

UI | Author Year | Outcome | Exposure Categories(e.g., Tertiles)/Intervention Groups | Mean Follow- up | Mean Ca level/dose | No. of Cases (Event) * | Total N | Crude or Adjusted analysis? | Outcome Metric (e.g. OR, RR, HR, %) | Outcome effect size | CI | P between groups *** | P for trend ****
8890661 | Dwyer 1996 | HTN (Rx) | Quartile 1 | 10 y | nd | nd | ~1658 | Adjusted (age) | % | 29.8% | | | nd
| | | Quartile 2 | | nd | nd | ~1658 | Unadjusted | % | ~27% (figure)
| | | Quartile 3 | | nd | nd | ~1658 | Unadjusted | % | ~25% (figure)
| | | Quartile 4 | | nd | nd | ~1658 | Adjusted (age) | % | 21.3%
| | HTN (Rx), Age ≤ 40 y | Quartile 2 | 10 y | nd | nd | nd | Adjusted | OR | 0.89 | 0.81, 0.97 | <.05 | <.05 younger vs older
| | | Quartile 3 | | nd | nd | nd | | | 0.79 | 0.66, 0.94 | <.05
| | | Quartile 4 | | nd | nd | nd | | | 0.70 | 0.54, 0.91 | <.05
| | HTN (Rx), Age >40 y | Quartile 2 | 10 y | nd | nd | nd | Adjusted | OR | 1.01 | 0.94, 1.08 | NS
| | | Quartile 3 | | nd | nd | nd | | | 1.02 | 0.89, 1.18 | NS
| | | Quartile 4 | | nd | nd | nd | | | 1.04 | 0.84, 1.28 | NS
| | HTN (Rx), Male | Quartile 2 | 10 y | nd | nd | nd | Adjusted | OR | 0.98 | 0.89, 1.08 | NS | NS male vs female
| | | Quartile 3 | | nd | nd | nd | | | 0.96 | 0.79, 1.17 | NS
| | | Quartile 4 | | nd | nd | nd | | | 0.95 | 0.70, 1.28 | NS
| | HTN (Rx), Female | Quartile 2 | 10 y | nd | nd | nd | Adjusted | OR | 0.96 | 0.89, 1.03 | NS
| | | Quartile 3 | | nd | nd | nd | | | 0.92 | 0.80, 1.07 | NS
| | | Quartile 4 | | nd | nd | nd | | | 0.87 | 0.71, 1.11 | NS
| | HTN (Rx), Black | Quartile 2 | 10 y | nd | nd | nd | Adjusted | OR | 0.94 | 0.82, 1.09 | NS | NS black vs white
| | | Quartile 3 | | nd | nd | nd | | | 0.86 | 0.67, 1.19 | NS
| | | Quartile 4 | | nd | nd | nd | | | 0.84 | 0.55, 1.29 | NS
| | HTN (Rx), White | Quartile 2 | 10 y | nd | nd | nd | Adjusted | OR | 0.97 | 0.91, 1.04 | NS
| | | Quartile 3 | | nd | nd | nd | | | 0.94 | 0.83, 1.08 | NS
| | | Quartile 4 | | nd | nd | nd | | | 0.92 | 0.75, 1.12 | NS

Duplicate one row per exposure category or intervention group.

* Number of subjects with outcome

** Please choose one and delete the others

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

**** P value for testing the linear trend of the OR/RR across different categories or doses

Age

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison* | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison* | Result | 95% CI | P btw | Result | 95% CI | P btw
8890661 | Dwyer 1996 | HTN (Rx) | Calcium intake, per 1 g/day increase | 10 year | nd | nd | OR (increase in Ca intake) Age ≤ 40 y | | | | 0.75 | nd | .004
| | | | | nd | nd | Age >40 y | | | | 1.00 | nd | .004
| | HTN (BP or Rx) | Calcium intake, per 1 g/day increase | 10 year | nd | nd | OR (increase in Ca intake) Age ≤ 40 y | | | | 0.83 | nd | .004
| | | | | nd | nd | Age >40 y | | | | 1.14 | nd | .004

Sex

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR,HR, %) and direction of comparison* | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR,HR, %) and direction of comparison* | Result | 95% CI | P btw | Result | 95% CI | P btw
8890661 | Dwyer 1996 | HTN (Rx) | Calcium intake, per 1 g/day increase | 10 year | nd | nd | OR (increase in Ca intake) Male | | | | 0.94 | nd | NS
| | | | | nd | nd | Female | | | | 0.85 | nd | NS
| | HTN (BP or Rx) | Calcium intake, per 1 g/day increase | 10 year | nd | nd | OR (increase in Ca intake) Male | | | | 1.10 | nd | NS
| | | | | nd | nd | Female | | | | 0.82 | nd | NS

Race

UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison* | Unadjusted | | | Adjusted
UI | Author Year | Outcome | Exposure/Intervention | Mean Follow-up, mo | N Event | N Total | Outcome Metric (e.g. OR, RR, HR, %) and direction of comparison* | Result | 95% CI | P btw | Result | 95% CI | P btw
8890661 | Dwyer 1996 | HTN (Rx) | Calcium intake, per 1 g/day increase | 10 year | nd | nd | OR (increase in Ca intake) Black | | | | 0.82 | nd | NS
| | | | | | | White | | | | 0.91 | nd | NS
| | HTN (BP or Rx) | Calcium intake, per 1 g/day increase | 10 year | nd | nd | OR (increase in Ca intake) Black | | | | 0.80 | nd | NS
| | | | | nd | nd | White | | | | 1.01 | nd | NS

QUALITY of COHORT OR NESTED CASE-CONTROL STUDIES

UI | Author Year | Population | | Exposure (All) | | Dietary assessment * | | Biomarkers * | | Comparator | | Statistical Analysis | | Outcome | | Design
8890661 | Dwyer 1996 | a) Eligibility criteria clear? (y/n) | Y | a) Exposure assessor blinded to outcome info? (y/n) | nd | a) Method reported? (y/n) | Y | a) One of the prespecified methods *** was used? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for ategoricalc analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | a) Clear definition of outcome, including time of ascertainment? (y/n) | Y | a) Prospective collection of data? (y/n) | Y
8890661 | Dwyer 1996 | b) Sampling of population random or consecutive? (y/n) | Y | b) Outcome assessor blinded to exposure measurement? (y/n) | nd | b) Food composition database or suppl composition reported? (y/n) | nd | Time from sample collection to sample analysis reported? (y/n) | NA | a) Level of the exposure in comparative categories (eg quartiles) is given (ranges)? (y/n) applicable for ategoricalc analyses only | Y | a) Adjusted or matched for ANY confounders (other than age and sex)? ** (y/n) | Y | b) Loss to follow-up <20%? (y/n) | Y | b) Analysis was planned when cohort was formed? (y/n) | ?
8890661 | Dwyer 1996 | | | | | c) Internal calibration of method perform (if FFQ)? (y/n/NA) | nd | | | | | b) Justification of final adjusted model selection? (y/n) | N | c) Do the authors specify a primary outcome? (y/n) | Y | c) Justification of sample size (includes sample size calculations)? (y/n) | N
OVERALL Grade (A/B/C): | | | | | | | C
Explanation for Overall Quality Grade (if not Grade A): | | | | | | | Thorough analyses. Incomplete data available from database. Methods not fully described. Numbers in subgroups and incident rates not fully enumerated.

* Check “NA” and skip all questions if study did not use dietary assessment or biomarkers

** We will judge in the end if the set of confounders is adequate

*** Prespecified methods: HPLC, RIA kits, LC-MS/MS; EIA/Chemiluminescence

## Eagan 2006

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
17189552 | Eagan 2006 | RCT-post hoc ** | Calcium intakes <800mg/d and energy intakes <2200kcal/d | > 20% overweight or 15% underweight according to the Metropolitan Life Insurance Tables | nd | nd | Dairy Management, Inc. (Rosemont, IL) | JHL

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake...etc.)
17189552 | Eagan 2006 | RCT- post hoc ** | Indiana 40°N | 154 | 51 | 19.4±1.6 | nd | 0 | nd | BMI: 22.31 Weight: 62.4kg | nd | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data…etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
17189552 | Eagan 2006 | 25(OH)D and/or 1,25(OH ^ ) ^ _ 2 _ D | | | | Immunosorbent assay (Dia-Sorin, Inc., Stillwater, MN) | n | nd | nd | 25(OH)D 24.5 ng/mL
17189552 | Eagan 2006 | Dietary calcium intake | 3-day food records | Food and Nutrient Database 28 (Minneapolis, MN) | n | nd | nd | | nd | Total Ca 723.5 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
17189552 | Eagan 2006 | High dairy | Foods from dairy | 1300–1400 mg Ca/day from dairy | 1y
17189552 | Eagan 2006 | Medium dairy | Foods from dairy | 1000–1100 mg Ca/day from dairy | 1y
17189552 | Eagan 2006 | Control | | Maintain current dietary consumption | 1y
Co-intervention(s) * : | | | None
Compliance/Adherence: | | | nd

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
17189552 | Eagan 2006 | nd | Weight | To the nearest 0.5 pound (1.1 kg), was measured using a standard physician’s balance beam scale
17189552 | Eagan 2006 | nd | BMI

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
17189552 | Eagan 2006 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | Yes–energy intake
17189552 | Eagan 2006 | Demographics (e.g., age, gender, race, education)? | No
17189552 | Eagan 2006 | Anthropometrics (e.g., BMI, body weight, % body fat)? | Yes * - BMI
17189552 | Eagan 2006 | Medical conditions
17189552 | Eagan 2006 | Medication
17189552 | Eagan 2006 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location)
17189552 | Eagan 2006 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | No
17189552 | Eagan 2006 | Other | 25(OH)D

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure Category/Intervention Group | Crude or Adjusted analysis? | Mean Follow-up (months) **** | No. Analyzed | Baseline | Baseline SD * | Final ** | Final SD * | Net difference *** | Net difference SD * | P between groups ***
17189552 | Eagan 2006 | Weight | Kg | High dairy | Adjusted | 18 months | 19 | 61.2 | 7.6 | 61.5 | 7.4 | 0.3 | 3.0 | NS
17189552 | Eagan 2006 | Weight | Kg | Medium dairy | Adjusted | 18 months | 14 | 66.1 | 13.7 | 66.3 | 14.8 | 0.1 | 6.7 | NS
17189552 | Eagan 2006 | Weight | Kg | Control | Adjusted | 18 months | 18 | 60.8 | 11.6 | 61.2 | 10.9 | 0.4 | 1.7 | NS
17189552 | Eagan 2006 | BMI | Kg/m ^ 2 ^ | High dairy | Adjusted | 18 months | 19 | 21.9 | 2.6 | 22.1 | 2.5 | 0.2 | 1.3 | NS
17189552 | Eagan 2006 | BMI | Kg/m ^ 2 ^ | Medium dairy | Adjusted | 18 months | 14 | 23.4 | 4.7 | 23.6 | 5.1 | 0.1 | 1.3 | NS
17189552 | Eagan 2006 | BMI | Kg/m ^ 2 ^ | Control | Adjusted | 18 months | 18 | 21.9 | 3.4 | 22.0 | 3.0 | 0.1 | 0.6 | NS

Duplicate one row per exposure category or intervention group. Please write “nd” if there was no data reported. DO NOT LEAVE BLANK.

* Please choose one and delete the others

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

*** Specify the comparison. For example group 1 vs. 3 = -6; group 1 vs. 2 = −8

**** Assessed the impact of the 1-year dairy intervention 6 months after completion of the intervention.

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
17189552 | Eagan 2006 | RCT- parallel | nd | n | NA | y | nd | y | y | y | Y | C
Adverse Event(s): ** | | | | | | Nd
Explanation for Overall Quality Grade (if not Grade A): | | | | | | Small number of subjects for the follow-up study (original study N=154, 135 completed one-year intervention, 51 subjects included in this study)

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT – Parallel, RCT – Cross-over, RCT – Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse.

## El-Hajj 2006

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

UI | Author Year | Study Design * | Inclusion | Exclusion | Enrollment Years | Trial or Cohort Name | Funding Source | Extractor
16278262 | El-Hajj 2006 | RCT | 10–17 yr girls in four schools from the greater Beirut area to ensure balanced representation geographically and socioeconomically | nd | 2001–2002 | nd | nd | JHL

* Leave appropriate choice of study design and delete all others

** Post hoc analyses of an existing RCT for outcomes that were not planned in the original RCT

POPULATION (BASELINE) **

UI | Author Year | Study Design * | Location (e.g., City and Country, latitude) | N enrolled *** | N analyzed | Mean (SD) Age, yr | Age Range/IQR | Male, % | Race/Ethnicity | Anthropometry data (e.g., BMI, weight, or %body fat ...etc) | Health Status | Specific Nutrition Status Data (e.g., malnourish, low Vit D or Ca intake ...etc.)
16278262 | El-Hajj 2006 | RCT | Greater Beirut area, Lebanon (33°53′N) | 179 | 168 | 13.2 (no sd) | 10–17y | 0% | nd | Height 152.7cm Weight 47.3 kg % fat mass 28.3% | Healthy | nd

* Please copy from above

** Report baseline data for all subjects: preferred data for subjects actually analyzed than for subjects that enrolled in the study.

*** For RCT, N enrolled is the number of subjects randomized. For cohort study, N enrolled is the total number of subjects fulfilled study inclusion criteria. For case-cohort study, please report as detailed as possible information on subjects selection. For example, original cohort sample size, number of subjects provided exposure data (eg. blood sample or dietary assessment), number of subjects had outcome data …etc.

Background Diet *

UI | Author Year | Exposure | Dietary Assessment Method ** | Food Composition Database *** | Internal Calibration (or Validity) of Dietary Assessment? (y/n) If Yes, Provide Data | Biomarker Assay **** | Analytical Validity of Biomarker Data Reported? (y/n) If Yes, Provide Data | Time between Biomarker Sampling and Analysis | Season/Date when the biomarker samples were drawn | Background exposure data
16278262 | El-Hajj 2006 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | 25(OH)D - Competitive protein biding assay | Y, intra- and interassay CVs less than 13% | nd | nd | 25(OH)D - 14.0 ng/ml
16278262 | El-Hajj 2006 | 25(OH)D and/or 1,25(OH) _ 2 _ D | | | | 1,25(OH)D - RIA | Y, intra- and interassay CVs less than 10% | nd | nd | 1,25(OH)D - 82.3 ng/ml
16278262 | El-Hajj 2006 | Dietary calcium intake | Food Frequency Questionnaire | nd | nd | nd | nd | | nd | 677.3 mg/d

* Write “nd” if there was no data reported. Please do not leave blank

** Please refer to common dietary assessment method table. If other method was used, please describe the detail. Otherwise, please simply use the brief name described in the table

*** USDA Nutrient Database, Minnesota Food and Nutrient Database (NDSR), Food product manufacturer, McCance and Widdowson's food table, Country-specific food tables, Other nutrient analysis (please specify)

**** ONLY biomarker of interest for calcium is calcium balance

INTERVENTION(S), SKIP IF OBSERVATIONAL STUDY

UI | Author Year | Vit D and/or Ca Intervention(s) | Source (e.g., brand name, foods, or formulation) | Vit D and/or Ca Total Daily Dose | Intervention Duration | Intervention Frequency (e.g. capsules were taken 2 times a day)
16278262 | El-Hajj 2006 | Low vitD | Diluted Vigantol oil, Merck KGaA, Darmstadt, Germany | 200IU/d | 1y | Weekly, usually taken on the weekends
16278262 | El-Hajj 2006 | High vitD | Vigantol oil, Merck KGaA, Darmstadt, Germany | 2000IU/d | 1y | Weekly, usually taken on the weekends
16278262 | El-Hajj 2006 | Placebo | Oily solution | nd | 1y | Weekly, usually taken on the weekends
Co-intervention(s) * : | | | None
Compliance/Adherence: | | | Placebo - 98%, Low dose group - 98%, High dose group - 97% Method - the % of the dose taken was calculated as (total volume-returned volume)/total volume * 100.

Duplicate one row per intervention, including control intervention.

* Report the non-vit D or Ca intervention(s) (e.g., other drug intervention, or background low-fat diet). We are interested in only independent effect of vitamin D and/or calcium. Therefore, describe how effects of co-intervention(s) were controlled for in the analyses or study design.

LIST OF ALL OUTCOMES

UI | Author Year | Primary/Secondary Outcome ** | Outcome | Definition
16278262 | El-Hajj 2006 | Primary | % change in BMC at the lumber spine
16278262 | El-Hajj 2006 | Primary | % change in total hip BMC
16278262 | El-Hajj 2006 | | 25(OH)D
16278262 | El-Hajj 2006 | | Height
16278262 | El-Hajj 2006 | | Weight

Duplicate one row per outcome of interest. Only need to list outcomes that were included in the result section.

** Must have been explicitly stated in the original paper. Otherwise, please enter “nd”

Confounders

Please report all confounders controlled in the analyses reported in the following result section (adjusted results)

UI | Author Year | Confounder Groups | Please List Name of Confounder (including matching factors) | Specific comments for confounders
16278262 | El-Hajj 2006 | Other nutrients or dietary factors (e.g., certain food consumption), including supplement use and total energy intake | | Dietary calcium intake was comparable across treatment groups and was not controlled for.
16278262 | El-Hajj 2006 | Demographics (e.g., age, gender, race, education)? | no * | Dietary calcium intake was comparable across treatment groups and was not controlled for.
16278262 | El-Hajj 2006 | Anthropometrics (e.g., BMI, body weight, % body fat)? | no * | Dietary calcium intake was comparable across treatment groups and was not controlled for.
16278262 | El-Hajj 2006 | Medical conditions | | Dietary calcium intake was comparable across treatment groups and was not controlled for.
16278262 | El-Hajj 2006 | Medication | | Dietary calcium intake was comparable across treatment groups and was not controlled for.
16278262 | El-Hajj 2006 | Sunlight exposure and its proxy variables (e.g., seasonal variation of 25(OH)D, UV exposure, location) | | Dietary calcium intake was comparable across treatment groups and was not controlled for.
16278262 | El-Hajj 2006 | Smoking and other life styles variables (e.g., physical activity, occupation, alcohol consumption) | no * | Dietary calcium intake was comparable across treatment groups and was not controlled for.
16278262 | El-Hajj 2006 | Other | | Dietary calcium intake was comparable across treatment groups and was not controlled for.

* Please choose “yes” if any one of the confounders in this group was controlled in the analysis

≥2 ARMS/GROUPS: CONTINOUS OUTCOMES (e.g. BMD, BP)

UI | Author Year | Outcome | Unit | Exposure Category/Intervention Group | Crude or Adjusted analysis? | Mean Follow-up (months) | No. Analyzed | Baseline | Baseline SD * | Final or Delta ** | Final SD * | Net difference *** | Net difference CI/SE/SD * | P between groups ***
16278262 | El-Hajj 2006 | 25(OH)D | ng/ml | Placebo | Adjusted | 1y | 55 | 14 | 7 | 16 | 8 | | | - Placebo vs. Low vitD=NS; - Placebo vs. High=p<0.001; - Low vitD vs. High vitD=p<0.001
| | | | Low vitD | Adjusted | 1y | 58 | 14 | 9 | 17 | 6 | | | - Placebo vs. Low vitD=NS; - Placebo vs. High=p<0.001; - Low vitD vs. High vitD=p<0.001
| | | | High vitD | Adjusted | 1y | 55 | 14 | 8 | 38 | 31 | | | - Placebo vs. Low vitD=NS; - Placebo vs. High=p<0.001; - Low vitD vs. High vitD=p<0.001
16278262 | El-Hajj 2006 | 1,25(OH)D | ng/ml | Placebo | Adjusted | 1y | 55 | 86 | 30 | 76 | 30 | | | - Placebo vs. Low vitD=NS; - Placebo vs. High=p<0.001; - Low vitD vs. High vitD=p<0.001
| | | | Low vitD | Adjusted | 1y | 58 | 78 | 29 | 78 | 30 | | | - Placebo vs. Low vitD=NS; - Placebo vs. High=p<0.001; - Low vitD vs. High vitD=p<0.001
| | | | High vitD | Adjusted | 1y | 55 | 83 | 27 | 105 | 33 | | | - Placebo vs. Low vitD=NS; - Placebo vs. High=p<0.001; - Low vitD vs. High vitD=p<0.001
16278262 | El-Hajj 2006 | Total body BMC | Kg | Placebo | Adjusted | 1y | 55 | 1.2 | 0.3 | Delta = 5.0 % | 4.7 | | | - Placebo vs. Low vitD=NS; - Placebo vs. High=NS; - Low vitD vs. High vitD=NS
| | | Kg | Low vitD | Adjusted | 1y | 58 | 1.1 | 0.3 | 6.1 % | 5.7 | | | - Placebo vs. Low vitD=NS; - Placebo vs. High=NS; - Low vitD vs. High vitD=NS
| | | Kg | High vitD | Adjusted | 1y | 55 | 1.1 | 0.3 | 6.2 % | 5.8 | | | - Placebo vs. Low vitD=NS; - Placebo vs. High=NS; - Low vitD vs. High vitD=NS
16278262 | El-Hajj 2006 | Height | cm | Placebo | Adjusted | 1y | 55 | 154 | 10 | Delta =2.0% | 1.8 | | | - Placebo vs. Low vitD=NS; - Placebo vs. High=NS; - Low vitD vs. High vitD=NS
| | | cm | Low vitD | Adjusted | 1y | 58 | 152 | 9 | 2.7% | 2.3 | | | - Placebo vs. Low vitD=NS; - Placebo vs. High=NS; - Low vitD vs. High vitD=NS
| | | cm | High vitD | Adjusted | 1y | 55 | 152 | 10 | 2.8% | 2.4 | | | - Placebo vs. Low vitD=NS; - Placebo vs. High=NS; - Low vitD vs. High vitD=NS
16278262 | El-Hajj 2006 | Weight | kg | Placebo | Adjusted | 1y | 55 | 48 | 11 | Delta =8.6% | 7.8 | | | - Placebo vs. Low vitD=NS; - Placebo vs. High=NS; - Low vitD vs. High vitD=NS
| | | kg | Low vitD | Adjusted | 1y | 58 | 47 | 11 | 8.8% | 8.3 | | | - Placebo vs. Low vitD=NS; - Placebo vs. High=NS; - Low vitD vs. High vitD=NS
| | | kg | High vitD | Adjusted | 1y | 55 | 47 | 13 | 9.7% | 8.5 | | | - Placebo vs. Low vitD=NS; - Placebo vs. High=NS; - Low vitD vs. High vitD=NS

Duplicate one row per exposure category or intervention group. Please write “nd” if there was no data reported. DO NOT LEAVE BLANK.

* Please choose one and delete the others

** Delta value is preferred than the Final value. Please report the direction for the change by using “+” or “−“ sign: e.g. +2.8 or −2.8

*** Specify the comparison. For example group 1 vs. 3 = −6; group 1 vs. 2 = −8

Premenarcheal girls (mean age = 10)

UI | Author Year | Outcome | Unit | Exposure Category/Intervention Group | Crude or Adjusted analysis? | Mean Follow-up (months) | No. Analyzed | Baseline | Baseline SD* | Final ** | Final SD* | Net difference*** | Net difference CI/SE/SD* | P between groups***
16278262 | El-Hajj 2006 | 25(OH)D | ng/ml | Placebo | Adjusted | 1y | 8 | 13 | 7 | 11 | 6 | | | Overall: <0.001 Placebo vs. Low=NS, Placebo vs. High=<0.001, Low vs. High=<0.001
| | | | Low vitD | Adjusted | 1y | 12 | 15 | 6 | 16 | 5 | | | Overall: <0.001 Placebo vs. Low=NS, Placebo vs. High=<0.001, Low vs. High=<0.001
| | | | High vitD | Adjusted | 1y | 14 | 14 | 5 | 28 | 9 | | | Overall: <0.001 Placebo vs. Low=NS, Placebo vs. High=<0.001, Low vs. High=<0.001
16278262 | El-Hajj 2006 | Total body BMC | kg | Placebo | Adjusted | 1y | 8 | 0.8 | 0.2 | Delta= 7.4 % | 3.9 | | | Overall: 0.06 Each pair comparison=NS
| | | kg | Low vitD | Adjusted | 1y | 12 | 0.7 | 0.2 | 11.4 % | 4.0 | | | Overall: 0.06 Each pair comparison=NS
| | | kg | High vitD | Adjusted | 1y | 14 | 0.8 | 0.2 | 11.6 % | 4.2 | | | Overall: 0.06 Each pair comparison=NS
16278262 | El-Hajj 2006 | Height | cm | Placebo | Adjusted | 1y | 8 | 142 | 8 | Delta=3.8% | 1.5 | | | Overall: 0.07 Each pair comparison=NS
| | | cm | Low vitD | Adjusted | 1y | 12 | 141 | 9 | 5.0% | 1.4 | | | Overall: 0.07 Each pair comparison=NS
| | | cm | High vitD | Adjusted | 1y | 14 | 140 | 7 | 5.6% | 1.3 | | | Overall: 0.07 Each pair comparison=NS
16278262 | El-Hajj 2006 | Weight | kg | Placebo | Adjusted | 1y | 8 | 37 | 11 | Delta=14.9% | 5.2 | | | Overall: 0.25 Each pair comparison=NS
| | | kg | Low vitD | Adjusted | 1y | 12 | 35 | 8 | 15.3% | 4.7 | | | Overall: 0.25 Each pair comparison=NS
| | | kg | High vitD | Adjusted | 1y | 14 | 36 | 8 | 18.4% | 6.2 | | | Overall: 0.25 Each pair comparison=NS

QUALITY of INTERVENTIONAL STUDIES

UI | Author Year | Design * | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Appropriate Washout Period (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis ** (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade
16278262 | El-Hajj 2006 | RCT-parallel | y | y | n | y | nd | y | y | y | y | C
Adverse Event(s): ** | | | | | | None
Explanation for Overall Quality Grade (if not Grade A): | | | | | | BMC - No adjustment for height, bone area, lean mass, pubertal stage, and bone age; rated C for ht and wt outcome because of small sample size (≤34)

NA=not applicable

* Please do not copy the 4 categories of study designs from above sections. Specify the exact study design: RCT–Parallel, RCT–Cross-over, RCT–Cluster, quasi-RCT, Non-randomized, but controlled trial, before-and-after trial, other interventional design (please explain in detail)

** Please do not leave blank. Type nd if there was no data on adverse