# Excluded Studies

Excluded Study | Reason
Aalberts JS, Weegels PL, van der HL et al. Calcium supplementation: effect on blood pressure and urinary mineral excretion in normotensive male lactoovovegetarians and omnivores. American Journal of Clinical Nutrition 48 (1):131–8, 1988. | No outcomes of interest
Abbasi AA, Chemplavil JK, Farah S, Muller BF, Arnstein AR. Hypercalcemia in active pulmonary tuberculosis. Annals of Internal Medicine 90 (3):324–8, 1979. | No UL outcomes
Abrams SA, Griffin IJ, Hawthorne KM, Ellis KJ. Effect of prebiotic supplementation and calcium intake on body mass index. Journal of Pediatrics 2007; 151(3):293–298. | Not a calcium intervention trial
Adams JS, Lee G. Gains in bone mineral density with resolution of Vitamin D intoxication. Annals of Internal Medicine 127 (3):203–6, 1997. | Case report
Akcakus M, Koklu E, Budak N, Kula M, Kurtoglu S, Koklu S. The relationship between birthweight, 25-hydroxyVitamin D concentrations and bone mineral status in neonates. Annals of Tropical Paediatrics2006; 26(4):267–275. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Ala-Houhala M, Koskinen T, Terho A, Koivula T, Visakorpi J. Maternal compared with infant Vitamin D supplementation. Archives of Disease in Childhood 61 (12):1159–63, 1986. | Not RCT arrow 4 study
Ala-Houhala M. 25-HydroxyVitamin D levels during breast-feeding with or without maternal or infantile supplementation of Vitamin D. Journal of Pediatric Gastroenterology & Nutrition 4(2):220–6, 1985. | In Ottawa EPC report
Almendingen K, Hofstad B, Vatn MH. Dietary habits and growth and recurrence of colorectal adenomas: results from a three-year endoscopic follow-up study. Nutrition & Cancer 49 (2):131–8, 2004. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Almendingen K, Hofstad B, Vatn MH. Lifestyle-related factors and colorectal polyps: preliminary results from a Norwegian follow-up and intervention study. European Journal of Cancer Prevention 11(2):153–8, 2002. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Almendingen K, Trygg K, Hofstad B, Veierod MB, Vatn MH. Results from two repeated 5 day dietary records with a 1 y interval among patients with colorectal polyps. European Journal of Clinical Nutrition55 (5):374–9, 2001. | No outcomes of interest
Al-oanzi ZH, Tuck SP, Raj N et al. Assessment of Vitamin D status in male osteoporosis. Clinical Chemistry 52 (2):248–54, 2006. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Aloia JF, Talwar SA, Pollack S, Feuerman M, Yeh JK. Optimal Vitamin D status and serum parathyroid hormone concentrations in African American women. American Journal of Clinical Nutrition 84 (3):602–9, 2006. | No outcomes of interest
Anonymous. Calcium supplementation during pregnancy reduces the risk of developing preeclampsia in nulliparous women. Canadian Family Physician 45:614, 618–20, 1999. | Editorial-like brief review
Anonymous. Vitamin D supplementation for northern native communities. Indian and Inuit Health Committee, Canadian Paediatric Society. CMAJ Canadian Medical Association Journal 138 (3):229–30, 1988. | Review paper
Armitage NC, Rooney PS, Gifford KA, Clarke PA, Hardcastle JD. The effect of calcium supplements on rectal mucosal proliferation. British Journal of Cancer 71 (1):186–90, 1995. | No outcomes of interest
Armstrong AL, Oborne J, Coupland CA, Macpherson MB, Bassey EJ, Wallace WA. Effects of hormone replacement therapy on muscle performance and balance in post-menopausal women. Clinical Science91 (6):685–90, 1996. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Arunabh S, Pollack S, Yeh J, Aloia JF. Body fat content and 25- hydroxyVitamin D levels in healthy women. Journal of Clinical Endocrinology & Metabolism 88 (1):157–61, 2003. | Cross-sectional or retrospective assessment of diet after disease diagnosis
August P, Helseth G, Cook EF, Sison C. A prediction model for superimposed preeclampsia in women with chronic hypertension during pregnancy. American Journal of Obstetrics & Gynecology. 191(5):1666–72, 2004 Nov. | >=20% subjects with diseases
August P, Marcaccio B, Gertner JM, Druzin ML, Resnick LM, Laragh JH. Abnormal 1,25-dihydroxyVitamin D metabolism in preeclampsia. American Journal of Obstetrics & Gynecology 166 (4):1295–9, 1992. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Back O, Blomquist HK, Hernell O, Stenberg B. Does vitamin D intake during infancy promote the development of atopic allergy? Acta Dermato-Venereologica 89 (1):28–32, 2009. | combination of vit D/Ca and other treatment w/o analysis of independent effect
Bailey BW, Sullivan DK, Kirk EP, Hall S, Donnelly JE. The influence of calcium consumption on weight and fat following 9 months of exercise in men and women. Journal of the American College of Nutrition 2007; 26(4):350–355. | No outcomes of interest
Bakker R, Rifas-Shiman SL, Kleinman KP, Lipshultz SE, Gillman MW. Maternal calcium intake during pregnancy and blood pressure in the offspring at age 3 years: a follow-up analysis of the Project Viva cohort. American Journal of Epidemiology 168 (12 ):1374–80, 2008. | age <18 (BP outcome)
Baron JA, Beach M, Mandel JS et al. Calcium supplements and colorectal adenomas. Polyp Prevention Study Group. Annals of the New York Academy of Sciences 889:138–45, 1999. | Duplicate publication (see Baron 1999 NEJM)
Baron JA, Beach M, Mandel JS et al. Calcium supplements for the prevention of colorectal adenomas. Calcium Polyp Prevention Study Group. . New England Journal of Medicine 340 (2):101–7, 1999. | In Weigarten 2008 systematic review
Baron JA, Tosteson TD, Wargovich MJ et al. Calcium supplementation and rectal mucosal proliferation: a randomized controlled trial.. Journal of the National Cancer Institute 87 (17):1303–7, 1995. | No outcomes of interest
Barr SI. Calcium and body fat in peripubertal girls: cross-sectional and longitudinal observations. Obesity 2007; 15(5):1302–1310. | Not RCT growth study
Barsoum GH, Hendrickse C, Winslet MC et al. Reduction of mucosal crypt cell proliferation in patients with colorectal adenomatous polyps by dietary calcium supplementation. British Journal of Surgery 79 (6):581–3, 1992. | No outcomes of interest
Basile LA, Taylor SN, Wagner CL, Horst RL, Hollis BW. The effect of high-dose Vitamin D supplementation on serum Vitamin D levels and milk calcium concentration in lactating women and their infants. Breastfeeding Medicine: The Official Journal of the Academy of Breastfeeding Medicine 2006; 1(1):27–35. | In Ottawa EPC report
Belizan JM, Villar J, Bergel E et al. Long-term effect of calcium supplementation during pregnancy on the blood pressure of offspring: follow up of a randomised controlled trial.. BMJ 315 (7103):281–5, 1997. | In Hofmeyer 2007 systematic review
Belizan JM, Villar J, Gonzalez L, Campodonico L, Bergel E. Calcium supplementation to prevent hypertensive disorders of pregnancy.. New England Journal of Medicine 325 (20):1399–405, 1991. | In Hofmeyer 2007 systematic review
Belizan JM, Villar J, Pineda O et al. Reduction of blood pressure with calcium supplementation in young adults. JAMA 249 (9):1161–5, 1983. | In systematic review
Belizan JM, Villar J, Zalazar A, Rojas L, Chan D, Bryce GF. Preliminary evidence of the effect of calcium supplementation on blood pressure in normal pregnant women. American Journal of Obstetrics & Gynecology 146 (2):175–80, 1983. | In Hofmeyer 2007 systematic review
Bell NH, Epstein S, Greene A, Shary J, Oexmann MJ, Shaw S. Evidence for alteration of the Vitamin D-endocrine system in obese subjects. Journal of Clinical Investigation 76 (1):370–3, 1985. | Not RCT arrow 4 study
Bell NH, Epstein S, Shary J, Greene V, Oexmann MJ, Shaw S. Evidence of a probable role for 25-hydroxyVitamin D in the regulation of human calcium metabolism. Journal of Bone & Mineral Research 3(5):489–95, 1988. | Not RCT arrow 4 study
Bell NH, Godsen RN, Henry DP, Shary J, Epstein S. The effects of muscle-building exercise on Vitamin D and mineral metabolism. Journal of Bone & Mineral Research 3(4):369–73, 1988. | No outcomes of interest
Bell NH. Hypercalcemic and hypocalcemic disorders: diagnosis and treatment. Nephron 23(2–3):147–51, 1979. | Review paper
Berggren M, Stenvall M, Olofsson B, Gustafson Y. Evaluation of a fall- prevention program in older people after femoral neck fracture: a one- year follow-up. Osteoporosis International 1919;801–9. | 100% patients with femoral neck fracture who admitted to the hospital
Berkey CS, Rockett HR, Willett WC, Colditz GA. Milk, dairy fat, dietary calcium, and weight gain: a longitudinal study of adolescents.. Archives of Pediatrics & Adolescent Medicine 159 (6):543–50, 2005. | Not RCT growth study
Berube S, Diorio C, Masse B et al. Vitamin D and calcium intakes from food or supplements and mammographic breast density. Cancer Epidemiology, Biomarkers & Prevention 14(7):1653–9, 2005. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Bierenbaum ML, Fleischman AI, Raichelson RI. Long term human studies on the lipid effects of oral calcium. Lipids 7 (3):202–6, 1972. | No outcomes of interest
Bierenbaum ML, Wolf E, Bisgeier G, Maginnis WP. Dietary calcium. A method of lowering blood pressure. American Journal of Hypertension1(3 Pt 3):149S–152S, 1988. | In systematic review
Bischoff HA, Stahelin HB, Dick W et al. Effects of Vitamin D and calcium supplementation on falls: a randomized controlled trial.. Journal of Bone & Mineral Research 18 (2):343–51, 2003. | In Ottawa EPC report
Bischoff-Ferrari HA, Conzelmann M, Stahelin HB et al. Is fall prevention by Vitamin D mediated by a change in postural or dynamic balance? Osteoporosis International 2006; 17(5):656–663. | Secondary analysis of an original RCT by Bischoff-Ferrari 2003, which is already in Ottawa’s report
Bischoff-Ferrari HA, Orav EJ, wson-Hughes B. Effect of cholecalciferol plus calcium on falling in ambulatory older men and women: a 3-year randomized controlled trial. Archives of Internal Medicine 166 (4):424–30, 2006. | In Ottawa EPC report
Blum M, Kirsten M, Worth MH, Jr. Reversible hypertension. Caused by the hypercalcemia of hyperparathyroidism, Vitamin D toxicity, and calcium infusion. JAMA 237 (3):262–3, 1977. | No 25(OH)D or dietary Ca
Boggess KA, Samuel L, Schmucker BC, Waters J, Easterling TR. A randomized controlled trial of the effect of third-trimester calcium supplementation on maternal hemodynamic function. Obstetrics & Gynecology 90 (2):157–61, 1997. | In Hofmeyer 2007 systematic review
Bonithon-Kopp C, Kronborg O, Giacosa A, Rath U, Faivre J. Calcium and fibre supplementation in prevention of colorectal adenoma recurrence: a randomised intervention trial. European Cancer Prevention Organisation Study Group. . Lancet 356 (9238):1300–6, 2000. | In Weigarten 2008 systematic review
Bonithon-Kopp C, Piard F, Fenger C et al. Colorectal adenoma characteristics as predictors of recurrence. Diseases of the Colon & Rectum 47 (3):323–33, 2004. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Boon N, Koppes LL, Saris WH, Van MW. The relation between calcium intake and body composition in a Dutch population: The Amsterdam Growth and Health Longitudinal Study. American Journal of Epidemiology 162 (1):27–32, 2005. | No outcomes of interest
Bostick RM, Fosdick L, Grandits GA, Grambsch P, Gross M, Louis TA. Effect of calcium supplementation on serum cholesterol and blood pressure. A randomized, double-blind, placebo-controlled, clinical trial. Archives of Family Medicine 9(1):31–8 2000. | >=20% subjects with diseases
Bostick RM, Fosdick L, Wood JR et al. Calcium and colorectal epithelial cell proliferation in sporadic adenoma patients: a randomized, double-blinded, placebo-controlled clinical trial.. Journal of the National Cancer Institute 87 (17):1307–15, 1995. | No outcomes of interest
Bostick RM, Potter JD, Fosdick L et al. Calcium and colorectal epithelial cell proliferation: a preliminary randomized, double-blinded, placebo-controlled clinical trial. Journal of the National Cancer Institute. 85(2):132–41, 1993 Jan 20. | No outcomes of interest
Boutron MC, Faivre J, Marteau P, Couillault C, Senesse P, Quipourt V. Calcium, phosphorus, Vitamin D, dairy products and colorectal carcinogenesis: a French case--control study.. British Journal of Cancer74 (1):145–51, 1996. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Bowen J, Noakes M, Clifton PM. Effect of calcium and dairy foods in high protein, energy-restricted diets on weight loss and metabolic parameters in overweight adults. International Journal of Obesity 29(8):957–65, 2005. | In systematic review
Braverman AS. Evidence that high calcium and Vitamin D intake decrease the risk of breast cancer in premenopausal women: implications for breast cancer prevention and screening. Southern Medical Journal100 (11):1061–2, 2007. | Review paper
Brekke HK, Ludvigsson J. Vitamin D supplementation and diabetes- related autoimmunity in the ABIS study. Pediatric Diabetes 2007; 8(1):11–14. | No 25(OH)D or dietary Ca
Broe KE, Chen TC, Weinberg J, Bischoff-Ferrari HA, Holick MF, Kiel DP. A higher dose of Vitamin d reduces the risk of falls in nursing home residents: a randomized, multiple-dose study. Journal of the American Geriatrics Society 2007; 55(2):234–239. | In Ottawa EPC report
Brooke OG, Butters F, Wood C. Intrauterine Vitamin D nutrition and postnatal growth in Asian infants. British Medical Journal Clinical Research Ed 283 (6298):1024, 1981. | No 25(OH)D or dietary Ca
Brooke OG. Supplementary Vitamin D in infancy and childhood. Archives of Disease in Childhood 1983; 58(8):573–574. | Review paper
Brunvand L, Quigstad E, Urdal P, Haug E. Vitamin D deficiency and fetal growth. Early Human Development 45 (1–2):27–33, 1996. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Brunvand L, Shah SS, Bergstrom S, Haug E. Vitamin D deficiency in pregnancy is not associated with obstructed labor. A study among Pakistani women in Karachi. Acta Obstetricia et Gynecologica Scandinavica 77 (3):303–6, 1998. | No outcomes of interest
Campbell CG, Chew BP, Luedecke LO, Shultz TD. Yogurt consumption does not enhance immune function in healthy premenopausal women. Nutrition & Cancer 37 (1):27–35, 2000. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Cancela L, Le BN, Miravet L. Relationship between the Vitamin D content of maternal milk and the Vitamin D status of nursing women and breast-fed infants. Journal of Endocrinology 110 (1):43–50, 1986. | Not RCT arrow 4 study
Canto-Costa MH, Kunii I, Hauache OM. Body fat and cholecalciferol supplementation in elderly homebound individuals. Brazilian Journal of Medical & Biological Research 39 (1):91–8, 2006. | Not RCT arrow 4 study
Caplan RH, Miller CD, Silva PD. Severe hypercalcemia in a lactating woman in association with moderate calcium carbonate supplementation: a case report. Journal of Reproductive Medicine 49(3):214–7, 2004. | Case report
Cappuccio FP, Elliott P, Allender PS, Pryer J, Follman DA, Cutler JA. Epidemiologic association between dietary calcium intake and blood pressure: a meta-analysis of published data. . American Journal of Epidemiology 142 (9):935–45, 1995. | Meta-analysis
Carlon GC, Howland WS, Goldiner PL, Kahn RC, Bertoni G, Turnbull AD. Adverse effects of calcium administration. Report of two cases. Archives of Surgery 113 (7):882–5, 1978. | Case report
Carlson LA, Derblom H, Lanner A. Effect of different doses of Vitamin D on serum cholesterol and triglyceride levels in healthy men. Atherosclerosis 12 (2): 313–7, 1970. | Multiple antioxidant trials analyses
Caruso JB, Patel RM, Julka K, Parish DC. Health-behavior induced disease: return of the milk-alkali syndrome. Journal of General Internal Medicine 2007; 22(7): 1053–1055. | Case report
Cats A, Kleibeuker JH, van der MR et al. Randomized, double-blinded, placebo-controlled intervention study with supplemental calcium in families with hereditary nonpolyposis colorectal cancer. Journal of the National Cancer Institute 87 (8): 598–603, 1995. | No outcomes of interest
Cervellin G, Bonino P, Palummeri E, Passeri M. Calcium phosphate and blood pressure: their relationships in a geriatric population. American Journal of Nephrology 6 Suppl 1: 16–8, 1986. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Chan GM, Roberts CC, Folland D, Jackson R. Growth and bone mineralization of normal breast-fed infants and the effects of lactation on maternal bone mineral status. American Journal of Clinical Nutrition 36 (3): 438–43, 1982. | In Ottawa EPC report
Chan GM. Growth and bone mineral status of discharged very low birth weight infants fed different formulas or human milk. Journal of Pediatrics 123 (3): 439–43, 1993. | >=20% subjects with diseases
Chan JM, Pietinen P, Virtanen M et al. Diet and prostate cancer risk in a cohort of smokers, with a specific focus on calcium and phosphorus (Finland). Cancer Causes & Control 11(9): 859–67, 2000. | Superseded by Mitrou 2007
Chen W, Dawsey SM, Qiao YL et al. Prospective study of serum 25(OH)-Vitamin D concentration and risk of oesophageal and gastric cancers. British Journal of Cancer 2007; 97(1): 123–128. | No outcomes of interest
Chyou PH, Nomura AM, Stemmermann GN. Diet, alcohol, smoking and cancer of the upper aerodigestive tract: a prospective study among Hawaii Japanese men. International Journal of Cancer 60 (5): 616–21, 1995. | No outcomes of interest
Cleghorn GJ, Tudehope DI. Neonatal intestinal obstruction associated with oral calcium supplementation. Australian Paediatric Journal 17(4): 298–9, 1981. | Case report
Cockburn F, Belton NR, Purvis RJ et al. Maternal Vitamin D intake and mineral metabolism in mothers and their newborn infants. British Medical Journal 281 (6232): 11–4, 1980. | Not RCT arrow 4 study
Cohen GR, Curet LB, Levine RJ et al. Ethnicity, nutrition, and birth outcomes in nulliparous women. American Journal of Obstetrics & Gynecology 2001; 185(3): 660–667. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Colditz GA, Manson JE, Stampfer MJ, Rosner B, Willett WC, Speizer FE. Diet and risk of clinical diabetes in women. American Journal of Clinical Nutrition 55 (5): 1018–23, 1992. | No outcomes of interest
Combs GF, Jr., Hassan N, Dellagana N et al. Apparent efficacy of food-based calcium supplementation in preventing rickets in Bangladesh. Biological Trace Element Research 121 (3): 193–204, 2008. | >=20% subjects with diseases
Cong K, Chi S, Liu G. Calcium supplementation during pregnancy forreducing pregnancy induced hypertension. Chinese Medical Journal 108 (1): 57–9, 1995. | In Hofmeyer 2007 systematic review
Corless D, Dawson E, Fraser F et al. Do Vitamin D supplements improve the physical capabilities of elderly hospital patients? Age & Ageing 14(2): 76–84, 1985. | In Ottawa EPC report
Cosman F, Nieves J, Shen V, Lindsay R. Oral 1,25-dihydroxyVitamin Dadministration in osteoporotic women: effects of estrogen therapy. Journal of Bone & Mineral Research 10(4): 594–600, 1995. | Not RCT arrow 4 study
Costenbader KH, Feskanich D, Holmes M, Karlson EW, ito-Garcia E. Vitamin D intake and risks of systemic lupus erythematosus and rheumatoid arthritis in women. Annals of the Rheumatic Diseases 67 (4): 530–5, 2008. | Observational study estimated Vitamin D supplement doses
Crowther CA, Hiller JE, Pridmore B et al. Calcium supplementation in nulliparous women for the prevention of pregnancy-induced hypertension, preeclampsia and preterm birth: an Australian randomized trial. FRACOG and the ACT Study Group. Australian & New Zealand Journal of Obstetrics & Gynaecology 39 (1): 12–8, 1999. | In Hofmeyer 2007 systematic review
Dahifar H, Faraji A, Yassobi S, Ghorbani A. Asymptomatic rickets in adolescent girls. Indian Journal of Pediatrics 2007; 74(6): 571–575. | Not RCT arrow 4 study
Dattani JT, Exton-Smith AN, Stephen JM. Vitamin D status of the elderly in relation to age and exposure to sunlight. Human Nutrition -Clinical Nutrition 38 (2): 131–7, 1984. | Not RCT arrow 4 study
Dauchet L, Kesse-Guyot E, Czernichow S et al. Dietary patterns and blood pressure change over 5-y follow-up in the SU.VI.MAX cohort. American Journal of Clinical Nutrition 2007; 85(6): 1650–1656. | No 25(OH)D or dietary Ca
Davie MW, Abraham RR, Hewins B, Wynn V. Changes in bone and muscle constituents during dieting for obesity. Clinical Science 70 (3): 285–93, 1986. | No outcomes of interest
Davies KM, Heaney RP, Recker RR et al. Calcium intake and body weight. Journal of Clinical Endocrinology & Metabolism 85 (12): 4635–8, 2000. | Meta-analysis; five clinical studies
Deheeger M, Bellisle F, Rolland-Cachera MF. The French longitudinal study of growth and nutrition: data in adolescent males and females. Journal of Human Nutrition & Dietetics 15 (6): 429–38, 2002. | Analysis did not relate exposure to outcome
DeJongh ED, Binkley TL, Specker BL. Fat mass gain is lower in calcium-supplemented than in unsupplemented preschool children with low dietary calcium intakes. American Journal of Clinical Nutrition 84 (5): 1123–7, 2006. | <9y (a study on BMI)
Dent CE, Gupta MM. Plasma 25-hydroxyVitamin-D-levels during pregnancy in Caucasians and in vegetarian and non-vegetarian Asians. Lancet 2(7944): 1057–60, 1975. | No outcomes of interest
DeSantiago S, Alonso L, Halhali A, Larrea F, Isoard F, Bourges H. Negative calcium balance during lactation in rural Mexican women. American Journal of Clinical Nutrition 76 (4): 845–51, 2002. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Devereux G, Litonjua AA, Turner SW et al. Maternal Vitamin D intake during pregnancy and early childhood wheezing. American Journal of Clinical Nutrition 2007; 85(3): 853–859. | No 25(OH)D or dietary Ca
Dewey KG, Lonnerdal B. Milk and nutrient intake of breast-fed infants from 1 to 6 months: relation to growth and fatness. Journal of Pediatric Gastroenterology & Nutrition 2(3): 497–506, 1983. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Dhesi JK, Bearne LM, Moniz C et al. Neuromuscular and psychomotor function in elderly subjects who fall and the relationship with Vitamin D status. Journal of Bone & Mineral Research 17(5): 891–7, 2002. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Dhesi JK, Jackson SH, Bearne LM et al. Vitamin D supplementation improves neuromuscular function in older people who fall. Age & Ageing 33 (6): 589–95, 2004. | Intramuscular injection of high dose ergocalciferol
Dijkstra SH, van BA, Janssen JW, de Vleeschouwer LH, Huysman WA, van den Akker EL. High prevalence of Vitamin D deficiency in newborn infants of high-risk mothers. [erratum appears in Arch Dis Child. 2007 Nov;92(11): 1049]. Archives of Disease in Childhood 2007; 92(9): 750–753. | Relationship betweem mother’s 25(OH)D and infant’s 25(OH)D levels
Dixon LB, Pellizzon MA, Jawad AF, Tershakovec AM. Calcium and dairy intake and measures of obesity in hyper- and normocholesterolemic children. Obesity Research 13(10): 1727–38, 2005. | Outcome is BW but participants age is from 4 to 10y (mostly <9y)
Dobnig H, Pilz S, Scharnagl H et al. Independent association of low serum 25-hydroxyvitamin d and 1,25-dihydroxyvitamin d levels with all-cause and cardiovascular mortality. Archives of Internal Medicine 168 (12): 1340–9, 2008. | >=20% subjects with diseases
Doege C, Bauer J. Effect of high volume intake of mother’s milk with an individualized supplementation of minerals and protein on early growth of preterm infants <28 weeks of gestation. Clinical Nutrition 26 (5): 581–8, 2007. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Domrongkitchaiporn S, Ongphiphadhanakul B, Stitchantrakul W et al. Risk of calcium oxalate nephrolithiasis after calcium or combined calcium and calcitriol supplementation in postmenopausal women. Osteoporosis International 11(6): 486–92, 2000. | No outcomes of interest, no UL outcomes
Drinka PJ, Nolten WE. Hazards of treating osteoporosis and hypertension concurrently with calcium, Vitamin D, and distal diuretics. Journal of the American Geriatrics Society 32 (5): 405–7, 1984. | Case report
Drouillet P, Balkau B, Charles MA et al. Calcium consumption and insulin resistance syndrome parameters. Data from the Epidemiological Study on the Insulin Resistance Syndrome (DESIR). Nutrition Metabolism & Cardiovascular Diseases 2007; 17(7): 486–492. | No outcomes of interest
Ehrenberg A. Non-medical prevention of pre-eclampsia. Acta Obstetricia et Gynecologica Scandinavica - Supplement 164: 108–10, 1997. | Review paper
Epstein S, Bell NH, Shary J, Shaw S, Greene A, Oexmann MJ. Evidence that obesity does not influence the Vitamin D-endocrine system in blacks. Journal of Bone & Mineral Research 1(2): 181–4, 1986. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Epstein S, Stern PH, Bell NH, Dowdeswell I, Turner RT. Evidence for abnormal regulation of circulating 1 alpha, 25-dihydroxyVitamin D in patients with pulmonary tuberculosis and normal calcium metabolism. Calcified Tissue International 36 (5): 541–4, 1984. | Not RCT arrow 4 study
Ertbeg P, Norgaard P, Bang L, Nyholm H, Rudnicki M. Ionized magnesium in gestational diabetes. Magnesium Research 17(1): 35–8, 2004. | No 25(OH)D or dietary Ca
Faivre J, Couillault C, Kronborg O et al. Chemoprevention of metachronous adenomas of the large bowel: design and interim results of a randomized trial of calcium and fibre. ECP Colon Group. European Journal of Cancer Prevention 6(2): 132–8, 1997. | Design and interim results article
Farrerons J, Barnadas M, Rodriguez J et al. Clinically prescribed sunscreen (sun protection factor 15) does not decrease serum Vitamin D concentration sufficiently either to induce changes in parathyroid function or in metabolic markers. British Journal of Dermatology 139 (3): 422–7, 1998. | No outcomes of interest
Faulkner KA, Cauley JA, Zmuda JM et al. Higher 1,25-dihydroxyVitamin D3 concentrations associated with lower fall rates in older community-dwelling women. Osteoporosis International 2006; 17(9): 1318–1328. | In Ottawa EPC report
Feeley RM, Eitenmiller RR, Jones JB, Jr., Barnhart H. Calcium, phosphorus, and magnesium contents of human milk during early lactation. Journal of Pediatric Gastroenterology & Nutrition 2(2): 262–7, 1983. | No outcomes of interest
Felson DT, Niu J, Clancy M et al. Low levels of Vitamin D and worsening of knee osteoarthritis: results of two longitudinal studies. Arthritis & Rheumatism 2007; 56(1): 129–136. | No outcomes of interest
Fleischman AR, Rosen JF, Cole J, Smith CM, DeLuca HF. Maternal and fetal serum 1,25-dihydroxyVitamin D levels at term. Journal of Pediatrics 1980; 97(4): 640–642. | No outcomes of interest
Fleischman AR, Rosen JF, Nathenson G. 25-hydroxyVitamin D. Serum levels and oral administration of calcifediol in neonates. Archives of Internal Medicine 138 Spec No: 869–73, 1978. | Premature infants
Forman JP, Bischoff-Ferrari HA, Willett WC, Stampfer MJ, Curhan GC. Vitamin D intake and risk of incident hypertension: results from three large prospective cohort studies. Hypertension 46 (4): 676–82, 2005. | No 25(OH)D or dietary Ca
Franco A, Sikalidis AK, Solis Herruzo JA. Colorectal cancer: influence of diet and lifestyle factors. Revista Espanola de Enfermedades Digestivas 97 (6): 432–48, 2005. | Review paper
Freedman DM, Tangrea JA, Virtamo J, Albanes D. The effect of beta-carotene supplementation on serum Vitamin D metabolite concentrations. Cancer Epidemiology, Biomarkers & Prevention 8 (12): 1115–6, 1999. | No outcomes of interest
Fronczak CM, Baron AE, Chase HP et al. In utero dietary exposures and risk of islet autoimmunity in children. Diabetes Care 26 (12): 3237–42, 2003. | Observational study estimated Vitamin D supplement doses
Galloe AM, Graudal N, Moller J, Bro H, Jorgensen M, Christensen HR. Effect of oral calcium supplementation on blood pressure in patients with previously untreated hypertension: a randomised, double-blind, placebo-controlled, crossover study. Journal of Human Hypertension 7 (1): 43–5, 1993. | In systematic review
Gambacciani M, Ciaponi M, Cappagli B et al. Body weight, body fat distribution, and hormonal replacement therapy in early postmenopausal women.[erratum appears in J Clin Endocrinol Metab 1997 Dec; 82(12): 4074]. Journal of Clinical Endocrinology & Metabolism 82 (2): 414–7, 1997. | No outcomes of interest
Garland CF, Garland FC. Do sunlight and Vitamin D reduce the likelihood of colon cancer? [reprint in Int J Epidemiol. 2006 Apr;35(2):217–20; PMID: 16303809]. International Journal of Epidemiology 9 (3): 227–31, 1980. | Ecological study
Garland CF, Mohr SB, Gorham ED, Grant WB, Garland FC. Role of ultraviolet B irradiance and Vitamin D in prevention of ovarian cancer. American Journal of Preventive Medicine 2006; 31(6): 512–514. | No 25(OH)D or dietary Ca
Genkinger JM, Hunter DJ, Spiegelman D et al. Dairy products and ovarian cancer: a pooled analysis of 12 cohort studies. Cancer Epidemiology, Biomarkers & Prevention 15 (2): 364–72, 2006. | Pooled analysis
Gertner JM, Domenech M. 25-HydroxyVitamin D levels in patients treated with high-dosage ergo- and cholecalciferol. Journal of Clinical Pathology 30(2): 144–50, 1977. | >=20% subjects with diseases
Gillies DR, Hay A, Sheltawy MJ, Congdon PJ. Effect of phototherapy on plasma 25(OH)-Vitamin D in neonates. Biology of the Neonate 1984; 45(5): 225–227. | Not RCT arrow 4 study
Gillman MW, Oliveria SA, Moore LL, Ellison RC. Inverse association of dietary calcium with systolic blood pressure in young children. JAMA 267 (17): 2340–3, 1992. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Gillman MW, Rifas-Shiman SL, Kleinman KP, Rich-Edwards JW, Lipshultz SE. Maternal calcium intake and offspring blood pressure. Circulation 110 (14): 1990–5, 2004. | Relationship between maternal intake and offspring blood pressure
Giovannucci E, Liu Y, Rimm EB et al. Prospective study of predictors of Vitamin D status and cancer incidence and mortality in men.. Journal of the National Cancer Institute 98 (7): 451–9, 2006. | Superseded by Giovannucci 2007
Giovannucci E, Rimm EB, Wolk A et al. Calcium and fructose intake in relation to risk of prostate cancer. Cancer Research 58 (3): 442–7, 1998. | Predictive model was used to predict 25(OH)D levels of whole cohort
Giovannucci E, Stampfer MJ, Colditz GA et al. MultiVitamin use, folate, and colon cancer in women in the Nurses’ Health Study.. Annals of Internal Medicine 129 (7): 517–24, 1998. | No 25(OH)D or dietary Ca
Gonzalez AJ, White E, Kristal A, Littman AJ. Calcium intake and 10-year weight change in middle-aged adults. Journal of the American Dietetic Association 106 (7): 1066–73 2006. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Goswami R, Gupta N, Ray D, Singh N, Tomar N. Pattern of 25-hydroxy vitamin D response at short (2 month) and long (1 year) interval after 8 weeks of oral supplementation with cholecalciferol in Asian Indians with chronic hypovitaminosis D. British Journal of Nutrition 100 (3):526–9, 2008. | not RCT curve 4 study
Grady D, Halloran B, Cummings S et al. 1,25-DihydroxyVitamin D3 and muscle strength in the elderly: a randomized controlled trial. Journal of Clinical Endocrinology & Metabolism 73 (5):1111–7, 1991. | 1,25(OH)2D supplement
Grant WB. The likely role of Vitamin D from solar ultraviolet-B irradiance in increasing cancer survival. Anticancer Research 26 (4A):2605–14, 2006. | Ecological study
Grau MV, Baron JA, Barry EL et al. Interaction of calcium supplementation and nonsteroidal anti-inflammatory drugs and the risk of colorectal adenomas. Cancer Epidemiology, Biomarkers & Prevention 14(10):2353–8, 2005. | In Weigarten 2008 systematic review
Greene MF. Trial of calcium to prevent preeclampsia. Journal of Women’s Health 6(4):485–6, 1997. | Commentary
Greer FR, Ho M, Dodson D, Tsang RC. Lack of 25-hydroxyVitamin D and 1,25-dihydroxyVitamin D in human milk. Journal of Pediatrics 99 (2):233–5, 1981. | No 25(OH)D or dietary Ca
Greer FR, Hollis BW, Cripps DJ, Tsang RC. Effects of maternal ultraviolet B irradiation on Vitamin D content of human milk. Journal of Pediatrics 105 (3):431–3, 1984. | No 25(OH)D or dietary Ca
Greer FR, Marshall S. Bone mineral content, serum Vitamin D metabolite concentrations, and ultraviolet B light exposure in infants fed human milk with and without Vitamin D2 supplements. Journal of Pediatrics 114 (2):204–12, 1989. | In Ottawa EPC report
Greer FR, Searcy JE, Levin RS, Steichen JJ, Asch PS, Tsang RC. Bone mineral content and serum 25-hydroxyVitamin D concentration in breast-fed infants with and without supplemental Vitamin D. Journal of Pediatrics 98 (5):696–701, 1981. | In Ottawa EPC report
Gruson M, Cancela L, Denne MA, Miravet L. Relationship between bone GLA-protein (BGP) and calcidiol (25-hydroxycalciferol) in serum of breast-fed infants. Endocrinologia Experimentalis. 20(2–3):329–34, 1986 Aug. | 25(OH)D supplement
Gunther CW, Legowski PA, Lyle RM et al. Dairy products do not lead to alterations in body weight or fat mass in young women in a 1-y intervention. American Journal of Clinical Nutrition 81 (4):751–6, 2005. | In systematic review
Gunther CW, Legowski PA, Lyle RM et al. Parathyroid hormone is associated with decreased fat mass in young healthy women. International Journal of Obesity 30 (1):94–9, 2006. | Ca intake and BW measured but not assessed ⇒ no relevant results reported
Haddad JG, Jr., Rojanasathit S. Acute administration of 25-hydroxycholecalciferol in man. Journal of Clinical Endocrinology & Metabolism 42 (2):284–90, 1976. | Not RCT arrow 4 study
Hakala P, Karvetti RL. Weight reduction on lactovegetarian and mixed diets. Changes in weight, nutrient intake, skinfold thicknesses and blood pressure. European Journal of Clinical Nutrition 43 (6):421–30, 1989. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Halhali A, Villa AR, Madrazo E et al. Longitudinal changes in maternal serum 1,25-dihydroxyVitamin D and insulin like growth factor I levels in pregnant women who developed preeclampsia: comparison with normotensive pregnant women. Journal of Steroid Biochemistry & Molecular Biology 89–90 (1–5):553–6, 2004. | No outcomes of interest
Hamet P, Mongeau E, Lambert J et al. Interactions among calcium, sodium, and alcohol intake as determinants of blood pressure. Hypertension 17(1 Suppl):I150–4, 1991. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Hamid Z, Riggs A, Spencer T, Redman C, Bodenner D. Vitamin D deficiency in residents of academic long-term care facilities despite having been prescribed Vitamin D.. Journal of the American Medical Directors Association 2007; 8(2):71–75. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Hansen KE, Jones AN, Lindstrom MJ, Davis LA, Engelke JA, Shafer MM. Vitamin D insufficiency: disease or no disease? Journal of Bone & Mineral Research 23(7):1052–60, 2008. | Not RCT arrow 4 study
Haub MD, Simons TR, Cook CM, Remig VM, Al-Tamimi EK, Holcomb CA. Calcium-fortified beverage supplementation on body composition in postmenopausal women. Nutrition Journal 4:21, 2005. | In systematic review
Heilbrun LK, Hankin JH, Nomura AM, Stemmermann GN. Colon cancer and dietary fat, phosphorus, and calcium in Hawaiian-Japanese men. American Journal of Clinical Nutrition 43 (2):306–9, 1986. | Letter to the editor
Heilbrun LK, Nomura A, Hankin JH, Stemmermann GN. Dietary Vitamin D and calcium and risk of colorectal cancer. Lancet 1985; 1(8434):925. | Superceded by Stemmermann, 1990 RefID 1691
Herrera JA, revalo-Herrera M, Herrera S. Prevention of preeclampsia by linoleic acid and calcium supplementation: a randomized controlled trial. Obstetrics & Gynecology 91 (4):585–90, 1998. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Herrmann U, Schwille PO, Schmiedl A, Fan J, Manoharan M. Acute effects of calcium sodium citrate supplementation of a test meal on mineral homeostasis, oxalate, and calcium oxalate crystallization in the urine of healthy humans--preliminary results in patients with idiopathic calcium urolithiasis. Biomedicine & Pharmacotherapy 53 (5–6):264–73, 1999. | No UL outcomes: CaOx crystallization; saturation of CaOx
Hill KM, Braun M, Kern M et al. Predictors of calcium retention in adolescent boys. Journal of Clinical Endocrinology & Metabolism 93 (12 ):4743–8, 2008. | no outcomes of interest
Hiller JE, Crowther CA, Moore VA, Willson K, Robinson JS. Calcium supplementation in pregnancy and its impact on blood pressure in children and women: follow up of a randomised controlled trial. Australian & New Zealand Journal of Obstetrics & Gynaecology 2007; 47(2):115–121. | No outcomes of interest
Hillman LS, Haddad JG. Perinatal Vitamin D metabolism. II. Serial 25-hydroxyVitamin D concentrations in sera of term and premature infants. Journal of Pediatrics 1975; 86(6):928–935. | No clear Vitamin D dose for term infants
Hillman LS, Johnson LS, Lee DZ, Vieira NE, Yergey AL. Measurement of true absorption, endogenous fecal excretion, urinary excretion, and retention of calcium in term infants by using a dual-tracer, stable-isotope method. Journal of Pediatrics 1993; 123(3):444–456. | All neonates included weighed < 1500 gm
Hintzpeter B, Mensink GB, Thierfelder W, Muller MJ, Scheidt-Nave C. Vitamin D status and health correlates among German adults. European Journal of Clinical Nutrition 62 (9 ):1079–89, 2008. | cross-sectional or retrospective assessment of diet after disease diagnosis
Hofmeyr GJ, Mlokoti Z, Nikodem VC et al. Calcium supplementation during pregnancy for preventing hypertensive disorders is not associated with changes in platelet count, urate, and urinary protein: a randomized control trial. Hypertension in Pregnancy 27 (3):299–304, 2008. | ancillary study (small sample) of WHO trial. The preeclampsia data of WHO trial was already included in the previous SR (Hofmeyer2007).
Hofstad B, Almendingen K, Vatn M et al. Growth and recurrence of colorectal polyps: a double-blind 3-year intervention with calcium and antioxidants. Digestion 59 (2):148–56, 1998. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Hofstad B, Vatn MH, Andersen SN, Owen RW, Larsen S, Osnes M. The relationship between faecal bile acid profile with or without supplementation with calcium and antioxidants on recurrence and growth of colorectal polyps. European Journal of Cancer Prevention 7 (4):287–94, 1998. | No independent Ca effect
Hollis BW, Wagner CL. Vitamin D requirements during lactation: high-dose maternal supplementation as therapy to prevent hypoVitaminosis D for both the mother and the nursing infant. Am J Clin Nutr 2004; 80(6 Suppl):1752S–1758S. | In Ottawa EPC report
Hollis JH, Mattes RD. Effect of increased dairy consumption on appetitive ratings and food intake. [erratum appears in Obesity (Silver Spring). 2007 Oct;15(10):2520]. Obesity 2007; 15(6):1520–1526. | No outcomes of interest
Holt PR, Atillasoy EO, Gilman J et al. Modulation of abnormal colonic epithelial cell proliferation and differentiation by low-fat dairy foods: a randomized controlled trial. . JAMA 280 (12):1074–9, 1998. | No outcomes of interest
Holt PR, Bresalier RS, Ma CK et al. Calcium plus Vitamin D alters preneoplastic features of colorectal adenomas and rectal mucosa. Cancer 106 (2):287–96, 2006. | No outcomes of interest
Holt PR, Wolper C, Moss SF, Yang K, Lipkin M. Comparison of calcium supplementation or low-fat dairy foods on epithelial cell proliferation and differentiation. Nutrition & Cancer 41 (1–2):150–5, 2001. | No outcomes of interest
Hunt CD, Johnson LK. Calcium requirements: new estimations for men and women by cross-sectional statistical analyses of calcium balance data from metabolic studies. American Journal of Clinical Nutrition 2007; 86(4):1054–1063. | Arrow 4: calcium balance
Hvarfner A, Ljunghall S, Morlin C, Wide L. Calcium metabolism and arterial blood pressure in a healthy population sample and in hypertensive men. American Journal of Nephrology 6 Suppl 1:14–5, 1986. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Hyman J, Baron JA, Dain BJ et al. Dietary and supplemental calcium and the recurrence of colorectal adenomas. Cancer Epidemiology, Biomarkers & Prevention 7 (4):291–5, 1998. | Multiple antioxidant trials analyses
Hypponen E, Hartikainen AL, Sovio U, Jarvelin MR, Pouta A. Does Vitamin D supplementation in infancy reduce the risk of pre-eclampsia? European Journal of Clinical Nutrition 2007; 61(9):1136–1139. | Observational study estimated Vitamin D supplement doses
Hypponen E, Laara E, Reunanen A, Jarvelin MR, Virtanen SM. Intake of Vitamin D and risk of type 1 diabetes: a birth-cohort study.. Lancet 358 (9292):1500–3, 2001. | Observational study estimated Vitamin D supplement doses
Hypponen E, Sovio U, Wjst M et al. Infant Vitamin d supplementation and allergic conditions in adulthood: northern Finland birth cohort 1966. Annals of the New York Academy of Sciences 1037:84–95, 2004. | Observational study estimated Vitamin D supplement doses
Ilich-Ernst JZ, McKenna AA, Badenhop NE et al. Iron status, menarche, and calcium supplementation in adolescent girls.[erratum appears in Am J Clin Nutr 1999 Mar;69(3):577]. American Journal of Clinical Nutrition 68 (4):880–7, 1998. | Ca intake, BMI, LBM and BW measured, but the analyses on the relationship among these were not performed.
Ish-Shalom S, Segal E, Salganik T, Raz B, Bromberg IL, Vieth R. Comparison of daily, weekly, and monthly vitamin D3 in ethanol dosing protocols for two months in elderly hip fracture patients. Journal of Clinical Endocrinology & Metabolism 93 (9 ):3430–5, 2008. | arrow 4 RCT but daily doses were the same in the comparison groups (comparison of daily, weekly versus monthly dose)
Ito M, Koyama H, Ohshige A, Maeda T, Yoshimura T, Okamura H. Prevention of preeclampsia with calcium supplementation and Vitamin D3 in an antenatal protocol. International Journal of Gynaecology & Obstetrics 47 (2):115–20, 1994. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Jackson RD, Donepudi S, Mysiw WJ. Epidemiology of fracture risk in the Women’s Health Initiative. Current Osteoporosis Reports 6 (4):155–61, 2008. | review paper
Jackson RD, Lacroix AZ, Cauley JA, McGowan J. The Women’s Health Initiative calcium-Vitamin D trial: overview and baseline characteristics of participants. Annals of Epidemiology 13(9 Suppl):S98–106, 2003. | Overview of trial participants
Jackson RD, Lacroix AZ, Gass M et al. Calcium plus Vitamin D supplementation and the risk of fractures.[erratum appears in N Engl J Med. 2006 Mar 9;354(10):1102]. New England Journal of Medicine 354 (7):669–83, 2006. | Same as Wactawski-Wende 2006 RefID 1967 in which longer f/up data reported
Jacobs D. Calcium and myocardial infarction. South African Medical Journal Suid -Afrikaanse Tydskrif Vir Geneeskunde 48 (13):523–7, 1974. | No 25(OH)D or dietary Ca
Jacobs ET, Alberts DS, Benuzillo J, Hollis BW, Thompson PA, Martinez ME. Serum 25(OH)D levels, dietary intake of Vitamin D, and colorectal adenoma recurrence. Journal of Steroid Biochemistry & Molecular Biology 2007; 103(3–5):752–756. | Analyses include 25(OH)D measurements taken after outcome (colorectal polyps) occurred.
Jacques PF, Felson DT, Tucker KL et al. Plasma 25-hydroxyVitamin D and its determinants in an elderly population sample. American Journal of Clinical Nutrition 66 (4):929–36, 1997. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Joffe GM, Esterlitz JR, Levine RJ et al. The relationship between abnormal glucose tolerance and hypertensive disorders of pregnancy in healthy nulliparous women. Calcium for Preeclampsia Prevention (CPEP) Study Group.. American Journal of Obstetrics & Gynecology 179 (4):1032–7, 1998. | No 25(OH)D or dietary Ca
John EM, Dreon DM, Koo J, Schwartz GG. Residential sunlight exposure is associated with a decreased risk of prostate cancer. Journal of Steroid Biochemistry & Molecular Biology 89–90 (1–5):549–52, 2004. | No 25(OH)D or dietary Ca
John WG, Noonan K, Mannan N, Boucher BJ. HypoVitaminosis D is associated with reductions in serum apolipoprotein A-I but not with fasting lipids in British Bangladeshis. American Journal of Clinical Nutrition 82 (3):517–22, 2005. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Johnson MA, Fischer JG, Park S. Vitamin D deficiency and insufficiency in the Georgia Older Americans Nutrition Program. Journal of Nutrition for the Elderly 27 (1–2):29–46 , 2008. | combination of vit D/Ca and other treatment w/o analysis of independent effect
Johnson NE, Smith EL, Freudenheim JL. Effects on blood pressure of calcium supplementation of women. American Journal of Clinical Nutrition 42 (1):12–7, 1985. | In systematic review
Jones G, Scott F. Low bone mass in premenopausal parous women: identification and the effect of an information and bone density feedback program. . Journal of Clinical Densitometry 2(2):109–15, 1999. | No outcomes of interest
Jorde R, Bonaa KH. Calcium from dairy products, Vitamin D intake, and blood pressure: the Tromso Study.. American Journal of Clinical Nutrition 71 (6):1530–5, 2000. | No outcomes of interest
Kampman E, Giovannucci E, van’, V et al. Calcium, Vitamin D, dairy foods, and the occurrence of colorectal adenomas among men and women in two prospective studies. Am J Epidemiol 1994; 139(1):16–29. | Same cohorts as Wu 2002 RefID 529 (HPFS & NHS) and same exposure outcome relationship but shorter follow-up
Karanja N, Morris CD, Illingworth DR, McCarron DA. Plasma lipids and hypertension: response to calcium supplementation. American Journal of Clinical Nutrition 45 (1):60–5, 1987. | No outcomes of interest
Karanja N, Morris CD, Rufolo P, Snyder G, Illingworth DR, McCarron DA. Impact of increasing calcium in the diet on nutrient consumption, plasma lipids, and lipoproteins in humans. . American Journal of Clinical Nutrition 59 (4):900–7, 1994. | No outcomes of interest
Kawano Y. Role of blood pressure monitoring in non-pharmacological management of hypertension. Blood Pressure Monitoring 7 (1):51–4, 2002. | Review paper
Kearney J, Giovannucci E, Rimm EB et al. Calcium, Vitamin D, and dairy foods and the occurrence of colon cancer in men. American Journal of Epidemiology 143 (9):907–17, 1996. | Longer followup data were published in Wu 2002
Kemi VE, Karkkainen MU, Karp HJ, Laitinen KA, Lamberg-Allardt CJ. Increased calcium intake does not completely counteract the effects of increased phosphorus intake on bone: an acute dose-response study in healthy females. British Journal of Nutrition 99 (4):832–9, 2008. | No outcomes of interest
Kenny AM, Bellantonio S, Gruman CA, Acosta RD, Prestwood KM. Effects of transdermal testosterone on cognitive function and health perception in older men with low bioavailable testosterone levels. Journals of Gerontology Series A-Biological Sciences & Medical Sciences 57 (5):M321–5, 2002. | No 25(OH)D or dietary Ca
Kenny AM, Biskup B, Robbins B, Marcella G, Burleson JA. Effects of Vitamin D supplementation on strength, physical function, and health perception in older, community-dwelling men. Journal of the American Geriatrics Society 51 (12):1762–7, 2003. | In Ottawa EPC report
Kesteloot H, Geboers J. Calcium and blood pressure. Lancet1(8276):813–5, 1982. | No 25(OH)D or dietary Ca
Khaw KT, Barrett-Connor E. Dietary potassium and stroke-associated mortality. A 12-year prospective population study. New England Journal of Medicine 316 (5):235–40, 1987. | Continuous Ca intake analysis only
Kigutha HN, van Staveren WA, Wijnhoven TM, Hautvast JG. Maternal nutritional status may be stressed by seasonal fluctuations in food availability: evidence from rural women in Kenya. International Journal of Food Sciences & Nutrition 46 (3):247–55, 1995. | Ca intake, BMI and BW measured, but analysis did not relate Ca intake to BMI/BW.
Knekt P, Laaksonen M, Mattila C et al. Serum Vitamin D and subsequent occurrence of type 2 diabetes. Epidemiology. 19(5):666–71, 2008 Sep. | No outcomes of interest
Knight KB, Keith RE. Calcium supplementation on normotensive and hypertensive pregnant women. American Journal of Clinical Nutrition 55 (4):891–5, 1992. | No outcomes of interest
Knox EG. Ischaemic-heart-disease mortality and dietary intake of calcium. Lancet 1(7818):1465–7, 1973. | Analysis @ region level, not individual level
Kobayashi E, Okubo Y, Suwazono Y et al. Association between urinary calcium excretion level and mortality in inhabitants of the Jinzu River basin area of Japan. Biological Trace Element Research 89(2):145–53, 2002. | No 25(OH)D or dietary Ca
Koh-Banerjee PK, Ferreira MP, Greenwood M et al. Effects of calcium pyruvate supplementation during training on body composition, exercise capacity, and metabolic responses to exercise. Nutrition 21(3):312–9, 2005. | No 25(OH)D or dietary Ca
Kokot F, Pietrek J, Srokowska S et al. 25-hydroxyVitamin D in patients with essential hypertension. Clinical Nephrology 16 (4):188–92, 1981. | On drug Rx for hypertension
Koralek DO, Bertone-Johnson ER, Leitzmann MF et al. Relationship between calcium, lactose, Vitamin D, and dairy products and ovarian cancer. Nutrition & Cancer 2006; 56(1):22–30. | No outcomes of interest
Kristal AR, Chi C, Tangen CM, Goodman PJ, Etzioni R, Thompson IM. Associations of demographic and lifestyle characteristics with prostate-specific antigen (PSA) concentration and rate of PSA increase. Cancer 106 (2):320–8, 2006. | No outcomes of interest
Kromhout D, Bosschieter EB, Coulander CD. Potassium, calcium, alcohol intake and blood pressure: the Zutphen Study. American Journal of Clinical Nutrition 41 (6):1299–304, 1985. | No outcomes of interest
Kulier R, de OM, Gulmezoglu AM, Villar J. Nutritional interventions for the prevention of maternal morbidity. International Journal of Gynaecology & Obstetrics 63 (3):231–46, 1998. | SR of prevention of maternal morbidity
Kumar R, Cohen WR, Silva P, Epstein FH. Elevated 1,25–dihydroxyVitamin D plasma levels in normal human pregnancy and lactation. Journal of Clinical Investigation 63 (2):342–4, 1979. | No outcomes of interest
Kuroda T, Shiraki M, Tanaka S, Ohta H. Contributions of 25- hydroxyvitamin D, co-morbidities and bone mass to mortality in Japanese postmenopausal women. Bone 44 (1):168–72, 2009. | >=20% subjects with diseases
Kynast-Gales SA, Massey LK. Effects of dietary calcium from dairy products on ambulatory blood pressure in hypertensive men.. Journal of the American Dietetic Association 92 (12):1497–501, 1992. | In systematic review
Laaksi I, Ruohola JP, Tuohimaa P et al. An association of serum Vitamin D concentrations < 40 nmol/L with acute respiratory tract infection in young Finnish men. American Journal of Clinical Nutrition 86 (3):714–7, 2007. | No outcomes of interest
Lakdawala DR, Widdowson EM. Vitamin-D in human milk. Lancet 1(8004):167–8, 1977. | No outcomes of interest
Lamberg-Allardt C, Larjosto M, Schultz E. 25-HydroxyVitamin D concentrations in maternal and cord blood at delivery and in maternal blood during lactation in Finland. Human Nutrition - Clinical Nutrition 38 (4):261–8, 1984. | Not RCT arrow 4 study
Lancia B, Tedesco M, Sergio G, Tenna M. Anthropometric and nutritional assessment in Italian elderly subjects. Journal of Nutrition, Health & Aging 1(3):174–80, 1997. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Lappe JM, Davies KM, Travers-Gustafson D, Heaney RP. Vitamin D status in a rural postmenopausal female population. Journal of the American College of Nutrition 2006; 25(5):395–402. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Laraia BA, Bodnar LM, Siega-Riz AM. Pregravid body mass index is negatively associated with diet quality during pregnancy. Public Health Nutrition 2007; 10(9):920–926. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Lasco A, Gaudio A, Morini E et al. Effect of long-term treatment with raloxifene on mammary density in postmenopausal women. Menopause 2006; 13(5):787–792. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Latham NK, Anderson CS, Lee A et al. A randomized, controlled trial of quadriceps resistance exercise and Vitamin D in frail older people: the Frailty Interventions Trial in Elderly Subjects (FITNESS). Journal of the American Geriatrics Society 51 (3):291–9, 2003. | In Ottawa EPC report
Le BN, Cancela L, Miravet L. Calcidiol in human milk. The effect of prohormone on Vitamin D status of breast fed unsupplemented infants. Endocrinologia Experimentalis. 20(2–3):325–8, 1986. | Correlation b/tw breastmilk 25(OH)D with infant’s serum 25(OH)D
Lee DC, Lee GY. The use of pamidronate for hypercalcemia secondary to acute Vitamin D intoxication. Journal of Toxicology - Clinical Toxicology 36 (7):719–21, 1998. | Case report
Lee WT, Leung SS, Wang SH et al. Double-blind, controlled calcium supplementation and bone mineral accretion in children accustomed to a low-calcium diet.. American Journal of Clinical Nutrition 60 (5):744–50, 1994. | In Winzenberg 2007 systematic review, no outcomes of interest
Levine AJ, Harper JM, Ervin CM et al. Serum 25-hydroxyVitamin D, dietary calcium intake, and distal colorectal adenoma risk. Nutrition & Cancer 2001; 39(1):35–41. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Levine RJ, Esterlitz JR, Raymond EG et al. Trial of Calcium for Preeclampsia Prevention (CPEP): rationale, design, and methods. Controlled Clinical Trials 17(5):442–69, 1996. | Methods for trial
Levine RJ, Hauth JC, Curet LB et al. Trial of calcium to prevent preeclampsia.. New England Journal of Medicine 337 (2):69–76, 1997. | In Hofmeyer 2007 systematic review
Lewandowski S, Rodgers AL. Renal response to lithogenic and anti-lithogenic supplement challenges in a stone-free population group. Journal of Renal Nutrition 14(3):170–9, 2004. | No UL outcomes: saturation of CaOx
Liebman M, Chopin LF, Carter E et al. Factors related to blood pressure in a biracial adolescent female population. Hypertension 8(10):843–50, 1986. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Lin PH, Appel LJ, Funk K et al. The PREMIER intervention helps participants follow the Dietary Approaches to Stop Hypertension dietary pattern and the current Dietary Reference Intakes recommendations. Journal of the American Dietetic Association 2007; 107(9):1541–1551. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Lin YC, Lyle RM, McCabe LD, McCabe GP, Weaver CM, Teegarden D. Dairy calcium is related to changes in body composition during a two-year exercise intervention in young women. Journal of the American College of Nutrition. 19(6):754–60, 2000 Nov-Dec. | No outcomes of interest
Lind L, Lithell H, Skarfors E, Wide L, Ljunghall S. Reduction of blood pressure by treatment with alphacalcidol. A double-blind, placebo-controlled study in subjects with impaired glucose tolerance. Acta Medica Scandinavica 223 (3):211–7, 1988. | >=20% subjects with diseases
Lipkin M, Friedman E, Winawer SJ, Newmark H. Colonic epithelial cell proliferation in responders and nonresponders to supplemental dietary calcium. Cancer Research 49 (1):248–54, 1989. | >=20% subjects with diseases
Lipkin M, Newmark H. Effect of added dietary calcium on colonic epithelial-cell proliferation in subjects at high risk for familial colonic cancer. New England Journal of Medicine 313 (22):1381–4, 1985. | No outcomes of interest
Liu LS. Epidemiology of hypertension and cardiovascular disease--China experience. Clinical & Experimental Hypertension - Part A, Theory & Practice 12 (5):831–44, 1990. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Liu S, Choi HK, Ford E et al. A prospective study of dairy intake and the risk of type 2 diabetes in women. Diabetes Care 29 (7):1579–84, 2006. | No 25(OH)D or dietary Ca
Ljunghall S, Lind L, Lithell H et al. Treatment with one-alpha-hydroxycholecalciferol in middle-aged men with impaired glucose tolerance--a prospective randomized double-blind study. Acta Medica Scandinavica 222 (4):361–7, 1987. | >=20% subjects with diseases
Lonzer MD, Imrie R, Rogers D, Worley D, Licata A, Secic M. Effects of heredity, age, weight, puberty, actiVitaminy, and calcium intake on bone mineral density in children. Clinical Pediatrics 35 (4):185–9, 1996. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Lopez-Jaramillo P, Delgado F, Jacome P, Teran E, Ruano C, Rivera J. Calcium supplementation and the risk of preeclampsia in Ecuadorian pregnant teenagers. Obstetrics & Gynecology 90 (2):162–7, 1997. | In Hofmeyer 2007 systematic review
Lopez-Jaramillo P, Narvaez M, Weigel RM, Yepez R. Calcium supplementation reduces the risk of pregnancy-induced hypertension in an Andes population. British Journal of Obstetrics & Gynaecology 96 (6):64855, 1989. | In Hofmeyer 2007 systematic review
Luft FC, Aronoff GR, Sloan RS, Fineberg NS, Weinberger MH. Short-term augmented calcium intake has no effect on sodium homeostasis. Clinical Pharmacology & Therapeutics 39 (4):414–9, 1986. | No outcomes of interest
Lutter CK, Rodriguez A, Fuenmayor G, Avila L, Sempertegui F, Escobar J. Growth and micronutrient status in children receiving a fortified complementary food. Journal of Nutrition 138 (2):379–88, 2008. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Lyle RM. Does baseline serum total calcium level influence the blood pressure response to calcium supplementation? A double-blind study. Netherlands Journal of Medicine 41 (1–2):48–55, 1992. | In systematic review
Lynch MF, Griffin IJ, Hawthorne KM, Chen Z, Hamzo M, Abrams SA. Calcium balance in 1–4-y-old children. American Journal of Clinical Nutrition 2007; 85(3):750–754. | Arrow 4: calcium balance
Ma J, Stampfer MJ, Gann PH et al. Vitamin D receptor polymorphisms, circulating Vitamin D metabolites, and risk of prostate cancer in United States physicians. Cancer Epidemiology, Biomarkers & Prevention 7 (5):385–90, 1998. | Main results had been previous published (Gann 1996, RefID 3783), and no additional usable data
Macdonald HM, New SA, Campbell MK, Reid DM. Longitudinal changes in weight in perimenopausal and early postmenopausal women: effects of dietary energy intake, energy expenditure, dietary calcium intake and hormone replacement therapy. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity 27 (6):669–76, 2003. | No outcomes of interest
Madore F, Stampfer MJ, Rimm EB, Curhan GC. Nephrolithiasis and risk of hypertension. American Journal of Hypertension 11(1 Pt 1):46–53, 1998. | No outcomes of interest
Malila N, Virtanen M, Pietinen P et al. A comparison of prospective and retrospective assessments of diet in a study of colorectal cancer. Nutrition & Cancer 32 (3):146–53, 1998. | Superseded by Pietinen 1999
Mandic-Puljek M, Mandic ML, Perl A, Kenjeric D. Calcium intake, food sources and seasonal variations in eastern Croatia. Collegium Antropologicum 29 (2):503–7, 2005. | No outcomes of interest
Manios Y, Moschonis G, Grammatikaki E, Katsaroli I, Kanelou P, Tanagra S. Nutrition education in postmenopausal women: changes in dietary and cardiovascular indices. Maturitas 2006; 55(4):338–347. | Nutrition education intervention study
Marangella M, Vitaminale C, Petrarulo M, Rovera L, Dutto F. Effects of mineral composition of drinking water on risk for stone formation and bone metabolism in idiopathic calcium nephrolithiasis. Clinical Science 91 (3):313–8, 1996. | No UL outcomes: saturation of CaOx
Markestad T, Kolmannskog S, Arntzen E, Toftegaard L, Haneberg B, Aksnes L. Serum concentrations of Vitamin D metabolites in exclusively breast-fed infants at 70 degrees north. Acta Paediatrica Scandinavica 73 (1):29–32, 1984. | No relation with 25(OH)D to growth outcome
Markestad T. Effect of season and Vitamin D supplementation on plasma concentrations of 25-hydroxyVitamin D in Norwegian infants. Acta Paediatrica Scandinavica 72 (6):817–21, 1983. | Not RCT arrow 4 study
Markestad T. Plasma concentrations of Vitamin D metabolites in unsupplemented breast-fed infants. European Journal of Pediatrics 141 (2):77–80, 1983. | No outcomes of interest
Marniemi J, Jarvisalo J, Toikka T, Raiha I, Ahotupa M, Sourander L. Blood Vitamins, mineral elements and inflammation markers as risk factors of vascular and non-vascular disease mortality in an elderly population. International Journal of Epidemiology 27 (5):799–807, 1998. | No 25(OH)D or dietary Ca
Martinez ME, Giovannucci EL, Colditz GA et al. Calcium, Vitamin D, and the occurrence of colorectal cancer among women. Journal of the National Cancer Institute 88 (19):1375–82, 1996. | Longer followup data were published in Wu 2002
Marx SJ, Swart EG, Jr., Hamstra AJ, DeLuca HF. Normal intrauterine development of the fetus of a woman receiving extraordinarily high doses of 1,25-dihydroxyVitamin D3. Journal of Clinical Endocrinology & Metabolism 51 (5):1138–42, 1980. | Case report
Masse PG, Tranchant CC, Jougleux JL, Coburn SP, Cole DE. Cardiovascular disease-risk factors in middle-aged osteopaenic women treated with calcium alone or combined to three nutrients essential to artery and bone collagen. Journal of Human Nutrition & Dietetics 21(2):117–28, 2008. | No outcomes of interest
Matheson NA. Letter: Multiple sclerosis and diet. Lancet 2 (7884):831, 1974. | Letter to the editor
Matsumoto T, Kubodera N. ED-71, a new active Vitamin D3, increases bone mineral density regardless of serum 25(OH)D levels in osteoporotic subjects. Journal of Steroid Biochemistry & Molecular Biology 2007; 103(3–5):584–586. | Vitamin D analog
Mawer EB, Berry JL, Sommer-Tsilenis E, Beykirch W, Kuhlwein A, Rohde BT. Ultraviolet irradiation increases serum 1,25-dihydroxyVitamin D in Vitamin-D-replete adults. Mineral & Electrolyte Metabolism 10(2):117–21, 1984. | Not RCT arrow 4 study
Mazess RB, Peppler WW, Chesnut CH, III, Nelp WB, Cohn SH, Zanzi I. Total body bone mineral and lean body mass by dual-photon absorptiometry. II. Comparison with total body calcium by neutron activation analysis. Calcified Tissue International 33 (4):361–3, 1981. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Mazess RB, Peppler WW, Harrison JE, McNeill KG. Total body bone mineral and lean body mass by dual-photon absorptiometry. III. Comparison with trunk calcium by neutron activation analysis. Calcified Tissue International 33 (4):365–8, 1981. | No 25(OH)D or dietary Ca
McCarron DA, Morris CD. Blood pressure response to oral calcium in persons with mild to moderate hypertension. A randomized, double-blind, placebo-controlled, crossover trial. Annals of Internal Medicine 103 (6 (Pt 1)):825–31, 1985. | In systematic review
Merlino LA, Curtis J, Mikuls TR et al. Vitamin D intake is inversely associated with rheumatoid arthritis: results from the Iowa Women’s Health Study.. Arthritis & Rheumatism 50(1):72–7, 2004. | Observational study estimated Vitamin D supplement doses
Methy N, Binquet C, Boutron-Ruault MC, Paillot B, Faivre J, Bonithon-Kopp C. Dietary fatty acids and recurrence of colorectal adenomas in a European intervention trial. Nutrition & Cancer 60 (5):560–7, 2008. | no 25(OH)D or dietary Ca
Michaud DS, Spiegelman D, Clinton SK, Rimm EB, Willett WC, Giovannucci E. Prospective study of dietary supplements, macronutrients, micronutrients, and risk of bladder cancer in US men. American Journal of Epidemiology 152 (12):1145–53, 2000. | No outcomes of interest
Misselwitz J, Hesse V, Markestad T. Nephrocalcinosis, hypercalciuria and elevated serum levels of 1,25-dihydroxy Vitamin D in children. Possible link to Vitamin D toxicity. Acta Paediatrica Scandinavica 79 (6–7):637–43, 1990. | Case report
Moerman CJ, Smeets FW, Kromhout D. Dietary risk factors for clinically diagnosed gallstones in middle-aged men. A 25-year follow-up study (the Zutphen Study). Annals of Epidemiology 4(3):248–54, 1994. | No outcomes of interest
Mohr SB, Garland CF, Gorham ED, Garland FC. The association between ultraviolet B irradiance, vitamin D status and incidence rates of type 1 diabetes in 51 regions worldwide. Diabetologia 51 (8):1391–8, 2008. | ecological study
Moller UK, Ramlau-Hansen CH, Rejnmark L, Heickendorff L, Henriksen TB, Mosekilde L. Postpartum Vitamin D insufficiency and secondary hyperparathyroidism in healthy Danish women. European Journal of Clinical Nutrition 2006; 60(10):1214–1221. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Morley R, Carlin JB, Dwyer T. Maternal calcium supplementation and cardiovascular risk factors in twin offspring.. International Journal of Epidemiology 33 (6):1304–9, 2004. | No 25(OH)D or dietary Ca
Morosetti M, Jankovic L, Palombo G et al. High-dose calcitriol therapy and progression of cardiac vascular calcifications. Journal of Nephrology 21(4):603–8, 2008;-Aug. | i.v. calcitriol
Morris CD, McCarron DA. Effect of calcium supplementation in an older population with mildly increased blood pressure. American Journal of Hypertension 5(4 Pt 1):230–7, 1992. | No outcomes of interest
Munger KL, Levin LI, Hollis BW, Howard NS, Ascherio A. Serum 25-hydroxyVitamin D levels and risk of multiple sclerosis. JAMA. 296(23):2832–8, 2006 Dec 20. | No outcomes of interest
Muray S, Marco MP, Craver L, Rue M, Valdivielso JM, Fernandez E. Influence of mineral metabolism parameters on pulse pressure in healthy subjects.. Clinical Nephrology 2006; 66(6):411–417. | No 25(OH)D or dietary Ca
Nakamura K, Nishiwaki T, Ueno K, Yamamoto M. Age-related decrease in serum 25-hydroxyVitamin D concentrations in the frail elderly: a longitudinal study. Journal of Bone & Mineral Metabolism 2007; 25(4):232–236. | Effect of aging on 25(OH) D
Nakamura R, Saruta T. Effect of calcium supplementation on blood pressure in essential hypertensive subjects. Japanese Journal of Medicine 26 (2):203–6, 1987. | No outcomes of interest
Nako Y, Fukushima N, Tomomasa T, Nagashima K, Kuroume T. Hyper Vitaminosis D after prolonged feeding with a premature formula. Pediatrics 1993; 92(6):862–864. | Case report
Narang NK, Gupta RC, Jain MK. Role of Vitamin D in pulmonary tuberculosis. Journal of the Association of Physicians of India 32 (2):185–8, 1984. | No outcomes of interest
Nayir A, Kadioglu A, Sirin A, Emre S, Tonguc E, Bilge I. Causes of increased renal medullary echogenicity in Turkish children. Pediatric Nephrology 9 (6):729–33, 1995. | Case report
Need AG, O’Loughlin PD, Horowitz M, Nordin BE. Relationship between fasting serum glucose, age, body mass index and serum 25 hydroxy Vitamin D in postmenopausal women. Clinical Endocrinology 62 (6):738–41, 2005. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Nieves JW, Barrett-Connor E, Siris ES, Zion M, Barlas S, Chen YT. Calcium and vitamin D intake influence bone mass, but not short-term fracture risk, in Caucasian postmenopausal women from the National Osteoporosis Risk Assessment (NORA) study. Osteoporosis International 1919;673–9. | not RCT bone study (postmenepausal women)
Nilas L, Christiansen C. Treatment with Vitamin D or its analogues does not change body weight or blood glucose level in postmenopausal women. International Journal of Obesity 8(5):407–11, 1984. | Review paper
Niromanesh S, Laghaii S, Mosavi-Jarrahi A. Supplementary calcium in prevention of pre-eclampsia. International Journal of Gynaecology & Obstetrics 74 (1):17–21, 2001. | In Hofmeyer 2007 systematic review
Nishimura K, Shima M, Tsugawa N et al. Long-term hospitalization during pregnancy is a risk factor for Vitamin D deficiency in neonates.[erratum appears in J Bone Miner Metab. 2003;21(4):253]. Journal of Bone & Mineral Metabolism 21(2):103–8, 2003. | No outcomes of interest
Nishiyama T. Effects of calcium on muscular training. Journal of Nutritional Science & Vitaminology 31 Suppl: S45–7, 1985. | Calcium only and bone/muscle outcomes
Nowak A, Pachocka L, Targosz U, Klosiewicz-Latoszek L. Dietary calcium and obesity in men. Roczniki Panstwowego Zakladu Higieny 58 (1):301–5, 2007. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Nowson C, Morgan T. Effect of calcium carbonate on blood pressure in normotensive and hypertensive people. Hypertension 13(6 Pt 1):630–9, 1989. | In systematic review
Obarzanek E, Hunsberger SA, Van HL et al. Safety of a fat-reduced diet: the Dietary Intervention Study in Children (DISC). Pediatrics 100 (1):51–9, 1997. | No outcomes of interest
Ochner CN, Lowe MR. Self-reported changes in dietary calcium and energy intake predict weight regain following a weight loss diet in obese women. Journal of Nutrition 2007; 137(10):2324–2328. | No outcomes of interest
Olafsdottir AS, Wagner KH, Thorsdottir I, Elmadfa I. Fat-soluble Vitamins in the maternal diet, influence of cod liver oil supplementation and impact of the maternal diet on human milk composition. Annals of Nutrition & Metabolism 45 (6):265–72, 2001. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Paganus A, Juntunen-Backman K, Savilahti E. Follow-up of nutritional status and dietary survey in children with cow’s milk allergy. Acta Paediatrica 81 (6–7):518–21, 1992. | >=20% subjects with diseases
Palacios C, Benedetti P, Fonseca S. Impact of calcium intake on body mass index in Venezuelan adolescents. Puerto Rico Health Sciences Journal 26 (3):199–204, 2007. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Park SB, Suh DH, Youn JI. A pilot study to assess the safety and efficacy of topical calcipotriol treatment in childhood psoriasis. Pediatric Dermatology 16 (4):321–5, 1999. | No 25(OH)D or dietary Ca
Pasch A, Frey FJ, Eisenberger U, Mohaupt MG, Bonny O. PTH and 1.25 vitamin D response to a low-calcium diet is associated with bone mineral density in renal stone formers. Nephrology Dialysis Transplantation 23(8):2563–70, 2008. | no outcomes of interest
Pehlivan I, Hatun S, Aydogan M, Babaoglu K, Gokalp AS. Maternal Vitamin D deficiency and Vitamin D supplementation in healthy infants. Turkish Journal of Pediatrics 45 (4):315–20, 2003;-Dec. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Peters U, Hayes RB, Chatterjee N et al. Circulating Vitamin D metabolites, polymorphism in Vitamin D receptor, and colorectal adenoma risk. Cancer Epidemiology, Biomarkers & Prevention 2004; 13(4):546–552. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Peters U, McGlynn KA, Chatterjee N et al. Vitamin D, calcium, and Vitamin D receptor polymorphism in colorectal adenomas. Cancer Epidemiology, Biomarkers & Prevention 2001; 10(12):1267–1274. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Pettifor JM, Bikle DD, Cavaleros M, Zachen D, Kamdar MC, Ross FP. Serum levels of free 1,25-dihydroxy Vitamin D in Vitamin D toxicity. Annals of Internal Medicine 122 (7):511–3, 1995. | Case report
Phillips SM, Bandini LG, Cyr H, Colclough-Douglas S, Naumova E, Must A. Dairy food consumption and body weight and fatness studied longitudinally over the adolescent period.. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity 27 (9):1106–13, 2003. | Not RCT growth study
Pilz S, Dobnig H, Fischer JE et al. Low Vitamin d levels predict stroke in patients referred to coronary angiography. Stroke 39 (9):2611–3, 2008. | >=20% subjects with diseases
Pilz S, Dobnig H, Winklhofer-Roob B et al. Low serum levels of 25-hydroxyVitamin D predict fatal cancer in patients referred to coronary angiography. Cancer Epidemiology, Biomarkers & Prevention 17(5):1228–33, 2008. | >=20% subjects with diseases
Pittard WB, III, Geddes KM, Hulsey TC, Hollis BW. How much Vitamin D for neonates? American Journal of Diseases of Children 145 (10):1147–9, 1991. | Not RCT arrow 4 study
Pittard WB, III, Geddes KM, Sutherland SE, Miller MC, Hollis BW. Longitudinal changes in the bone mineral content of term and premature infants.. American Journal of Diseases of Children 1990; 144(1):36–40. | Changes in 25(OH)D status of term and premature infants
Pittas AG, Harris SS, Stark PC, wson-Hughes B. The effects of calcium and Vitamin D supplementation on blood glucose and markers of inflammation in nondiabetic adults.. Diabetes Care 2007; 30(4):980–986. | No outcomes of interest
Porojnicu AC, Robsahm TE, Dahlback A et al. Seasonal and geographical variations in lung cancer prognosis in Norway. Does Vitamin D from the sun play a role? Lung Cancer 2007; 55(3):263–270. | Ecological study
Prentice A, Ginty F, Stear SJ, Jones SC, Laskey MA, Cole TJ. Calcium supplementation increases stature and bone mineral mass of 16- to 18-year-old boys. Journal of Clinical Endocrinology & Metabolism 90 (6):3153–61, 2005. | In Winzenberg 2007 systematic review
Prineas RJ, Folsom AR, Zhang ZM, Sellers TA, Potter J. Nutrition and other risk factors for renal cell carcinoma in postmenopausal women. Epidemiology 8 (1):31–6, 1997. | No outcomes of interest
Purwar M, Kulkarni H, Motghare V, Dhole S. Calcium supplementation and prevention of pregnancy induced hypertension. Journal of Obstetrics & Gynaecology Research 22 (5):425–30, 1996. | In Hofmeyer 2007 systematic review
Rajalakshmi R, Sail SS, Shah DG, Ambady SK. The effects of supplements varying in carotene and calcium content on the physical, biochemical and skeletal status of preschool children. British Journal of Nutrition 30 (1):77–86, 1973. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Rajpathak SN, Rimm EB, Rosner B, Willett WC, Hu FB. Calcium and dairy intakes in relation to long-term weight gain in US men. American Journal of Clinical Nutrition 83 (3):559–66, 2006. | No outcomes of interest
Rees GA, Doyle W, Srivastava A, Brooke ZM, Crawford MA, Costeloe KL. The nutrient intakes of mothers of low birth weight babies - a comparison of ethnic groups in East London, UK. Maternal & Child Nutrition 1(2):91–9, 2005. | No outcomes of interest
Repke JT, Villar J, Anderson C, Pareja G, Dubin N, Belizan JM. Biochemical changes associated with blood pressure reduction induced by calcium supplementation during pregnancy. American Journal of Obstetrics & Gynecology 160 (3):684–90, 1989. | In Hofmeyer 2007 systematic review
Repke JT, Villar J. Pregnancy-induced hypertension and low birth weight: the role of calcium. American Journal of Clinical Nutrition 1991; 54(1:Suppl): Suppl-241S. | Review paper
Resnick LM, Oparil S, Chait A et al. Factors affecting blood pressure responses to diet: the Vanguard study. American Journal of Hypertension 13(9):956–65, 2000. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Reunanen A, Knekt P, Marniemi J, Maki J, Maatela J, Aromaa A. Serum calcium, magnesium, copper and zinc and risk of cardiovascular death. European Journal of Clinical Nutrition 50 (7):431–7, 1996. | No 25(OH)D or dietary Ca
Rich GM, McCullough M, Olmedo A, Malarick C, Moore TJ. Blood pressure and renal blood flow responses to dietary calcium and sodium intake in humans. American Journal of Hypertension 4(11):642S–645S, 1991. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Roberts CC, Chan GM, Folland D, Rayburn C, Jackson R. Adequate bone mineralization in breast-fed infants. Journal of Pediatrics 99 (2):192–6, 1981. | In Ottawa EPC report
Robien K, Cutler GJ, Lazovich D. Vitamin D intake and breast cancer risk in postmenopausal women: the Iowa Women’s Health Study. Cancer Causes & Control 2007; 18(7):775–782. | Observational study estimated Vitamin D supplement doses
Rogers MS, Fung HY, Hung CY. Calcium and low-dose aspirin prophylaxis in women at high risk of pregnancy-induced hypertension. Hypertension in Pregnancy 18 (2):165–72, 1999. | In Hofmeyer 2007 systematic review
Roongpisuthipong C, Kantawan R, Roongpisuthipong W. Reduction of adipose tissue and body weight: effect of water soluble calcium hydroxycitrate in Garcinia atroviridis on the short term treatment of obese women in Thailand. Asia Pacific Journal of Clinical Nutrition 2007; 16(1):25–29. | No 25(OH)D or dietary Ca
Rosell M, Hakansson NN, Wolk A. Association between dairy food consumption and weight change over 9 y in 19,352 perimenopausal women. American Journal of Clinical Nutrition 2006; 84(6):1481–1488. | Ca intake and BW measured but not assessed ==> no relevant results reported
Rothberg AD, Pettifor JM, Cohen DF, Sonnendecker EW, Ross FP. Maternal-infant Vitamin D relationships during breast-feeding. Journal of Pediatrics 101 (4):500–3, 1982. | In Ottawa EPC report
Rourke KM, Brehm BJ, Cassell C, Sethuraman G. Effect of weight change on bone mass in female adolescents. Journal of the American Dietetic Association 103 (3):369–72, 2003. | No 25(OH)D or dietary Ca
Rozen P, Fireman Z, Fine N, Wax Y, Ron E. Oral calcium suppresses increased rectal epithelial proliferation of persons at risk of colorectal cancer. Gut 30(5):650–5, 1989. | No outcomes of interest
Rozen P, Lubin F, Papo N et al. Calcium supplements interact significantly with long-term diet while suppressing rectal epithelial proliferation of adenoma patients. Cancer 91 (4):833–40, 2001. | No outcomes of interest
Rumiris D, Purwosunu Y, Wibowo N, Farina A, Sekizawa A. Lower rate of preeclampsia after antioxidant supplementation in pregnant women with low antioxidant status. Hypertension in Pregnancy 2006; 25(3):241–253. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Rush D, Sloan NL, Leighton J et al. The National WIC Evaluation: evaluation of the Special Supplemental Food Program for Women, Infants, and Children. V. Longitudinal study of pregnant women. American Journal of Clinical Nutrition 48 (2 Suppl):439–83, 1988. | No exposure of interest
Saadi HF, Dawodu A, Afandi B et al. Effect of combined maternal and infant vitamin D supplementation on vitamin D status of exclusively breastfed infants. Maternal & Child Nutrition 5(1):25–32, 2009. | arrow 4 RCT but daily doses were the same in the comparison groups (comparison of daily vs. monthly doses)
Sacks FM, Brown LE, Appel L, Borhani NO, Evans D, Whelton P. Combinations of potassium, calcium, and magnesium supplements in hypertension. Hypertension 26 (6 Pt 1):950–6, 1995. | Combinations of minerals
Sacks FM, Obarzanek E, Windhauser MM et al. Rationale and design of the Dietary Approaches to Stop Hypertension trial (DASH). A multicenter controlled-feeding study of dietary patterns to lower blood pressure. Annals of Epidemiology 5(2):108–18, 1995. | No outcomes of interest
Sacks FM, Willett WC, Smith A, Brown LE, Rosner B, Moore TJ. Effect on blood pressure of potassium, calcium, and magnesium in women with low habitual intake. Hypertension 31 (1):131–8, 1998. | In systematic review
Saito K, Sano H, Kawahara J, Yokoyama M. Calcium supplementation attenuates an enhanced platelet function in salt-loaded mildly hypertensive patients. Hypertension 26 (1):156–63, 1995. | Data too incomplete
Sakhaee K, Baker S, Zerwekh J, Poindexter J, Garcia-Hernandez PA, Pak CY. Limited risk of kidney stone formation during long-term calcium citrate supplementation in nonstone forming subjects. Journal of Urology 152 (2 Pt 1):324–7, 1994. | No UL outcomes
Sakhaee K, Poindexter JR, Griffith CS, Pak CY. Stone forming risk of calcium citrate supplementation in healthy postmenopausal women. Journal of Urology 172 (3):958–61, 2004. | No UL outcomes: saturation of CaOx
Salazar-Martinez E, Lazcano-Ponce E, Sanchez-Zamorano LM, Gonzalez-Lira G, Escudero-DE Los RP, Hernandez-Avila M. Dietary factors and endometrial cancer risk. Results of a case-control study in Mexico. International Journal of Gynecological Cancer 15 (5):938–45, 2005. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Sampath V, Havel PJ, King JC. Calcium supplementation does not alter lipid oxidation or lipolysis in overweight/obese women. Obesity 16(11):2400–4, 2008. | not RCT wt study
Sanchez-Ramos L, Adair CD, Kaunitz AM, Briones DK, DelValle GO, Delke I. Calcium supplementation in mild preeclampsia remote from term: a randomized double-blind clinical trial. Obstetrics & Gynecology 85 (6):915–8, 1995. | 100% patients with already diagnosed “mild” preeclampsia
Sanchez-Ramos L, Briones DK, Kaunitz AM, Delvalle GO, Gaudier FL, Walker CD. Prevention of pregnancy-induced hypertension by calcium supplementation in angiotensin II-sensitive patients. Obstetrics & Gynecology 84 (3):349–53, 1994. | In Hofmeyer 2007 systematic review
Sanders TA, Purves R. An anthropometric and dietary assessment of the nutritional status of vegan preschool children. Journal of Human Nutrition 35 (5):349–57, 1981. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Sato K, Emoto N, Toraya S et al. Progressively increased serum 1,25-dihydroxyVitamin D2 concentration in a hypoparathyroid patient with protracted hypercalcemia due to Vitamin D2 intoxication. Endocrine Journal 41 (4):329–37, 1994. | Case report
Satterfield S, Cutler JA, Langford HG et al. Trials of hypertension prevention. Phase I design. Annals of Epidemiology 1(5):455–71, 1991. | Shows research design, but no result
Schleithoff SS, Zittermann A, Tenderich G, Berthold HK, Stehle P, Koerfer R. Vitamin D supplementation improves cytokine profiles in patients with congestive heart failure: a double-blind, randomized, placebo-controlled trial.[see comment]. American Journal of Clinical Nutrition 83 (4):754–9, 2006. | >=20% subjects with diseases
Schumann SA, Ewigman B. Double-dose Vitamin D lowers cancer risk in women over 55. Journal of Family Practice 2007; 56(11):907–910. | Editorial-like brief review
Sellers TA, Bazyk AE, Bostick RM et al. Diet and risk of colon cancer in a large prospective study of older women: an analysis stratified on family history (Iowa, United States). Cancer Causes & Control 9(4):357–67, 1998. | Same cohort as Zheng 1998 (RefID 2924) only difference is that taking into consideration the family history of colon cancer in the analysis
Shahar DR, Abel R, Elhayany A, Vardi H, Fraser D. Does dairy calcium intake enhance weight loss among overweight diabetic patients? Diabetes Care 2007; 30(3):485–489. | >=20% subjects with diseases
Shapses SA, Heshka S, Heymsfield SB. Effect of calcium supplementation on weight and fat loss in women. Journal of Clinical Endocrinology & Metabolism 89 (2):632–7, 2004. | In systematic review
Sharkey JR, Giuliani C, Haines PS, Branch LG, Busby-Whitehead J, Zohoori N. Summary measure of dietary musculoskeletal nutrient (calcium, Vitamin D, magnesium, and phosphorus) intakes is associated with lower-extremity physical performance in homebound elderly men and women. American Journal of Clinical Nutrition 77 (4):847–56, 2003. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Shaunak S, Ang L, Colston K, Patel S, Bland M, Maxwell JD. Muscle strength in healthy white and Asian subjects: the relationship of quadriceps maximum voluntary contraction to age, sex, body build and Vitamin D. Clinical Science 73 (5):541–6, 1987. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Sibai BM, Ewell M, Levine RJ et al. Risk factors associated with preeclampsia in healthy nulliparous women. The Calcium for Preeclampsia Prevention (CPEP) Study Group.. American Journal of Obstetrics & Gynecology 177 (5):1003–10, 1997. | No Ca dose
Sieg J, Sieg A, Dreyhaupt J, Schmidt-Gayk H. Insufficient Vitamin D supply as a possible co-factor in colorectal carcinogenesis. Anticancer Research 26 (4A):2729–33, 2006. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Silverman SL, Delmas PD, Kulkarni PM, Stock JL, Wong M, Plouffe L, Jr. Comparison of fracture, cardiovascular event, and breast cancer rates at 3 years in postmenopausal women with osteoporosis. Journal of the American Geriatrics Society 52 (9):1543–8, 2004. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Sita-Lumsden A, Lapthorn G, Swaminathan R, Milburn HJ. Reactivation of tuberculosis and Vitamin D deficiency: the contribution of diet and exposure to sunlight. Thorax 62 (11):1003–7, 2007. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Siwek RA, Burkinshaw L, Oxby CB, Robinson PA. Multi-element analysis of the obese subject by in vivo neutron activation analysis. Physics in Medicine & Biology 29 (6):687–701, 1984. | Not relevant
Skinner JD, Bounds W, Carruth BR, Ziegler P. Longitudinal calcium intake is negatively related to children’s body fat indexes.. Journal of the American Dietetic Association 103 (12):1626–31, 2003. | Not RCT growth study
Slemenda CW, Reister TK, Hui SL, Miller JZ, Christian JC, Johnston CC, Jr. Influences on skeletal mineralization in children and adolescents: evidence for varying effects of sexual maturation and physical actiVitaminy. Journal of Pediatrics 125 (2):201–7, 1994. | No 25(OH)D or dietary Ca
Specker BL, Beck A, Kalkwarf H, Ho M. Randomized trial of varying mineral intake on total body bone mineral accretion during the first year of life. Pediatrics 99(6): E12, 1997. | No independent Ca effect
Specker BL, Tsang RC, Ho M, Miller D. Effect of vegetarian diet on serum 1,25-dihydroxyVitamin D concentrations during lactation. Obstetrics & Gynecology 70 (6):870–4, 1987. | No 25(OH)D or dietary Ca
Specker BL, Valanis B, Hertzberg V, Edwards N, Tsang RC. Sunshine exposure and serum 25-hydroxyVitamin D concentrations in exclusively breast-fed infants. Journal of Pediatrics 107 (3):372–6, 1985. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Stamler J, Liu K, Ruth KJ, Pryer J, Greenland P. Eight-year blood pressure change in middle-aged men: relationship to multiple nutrients. Hypertension 39 (5):1000–6, 2002. | No outcomes of interest
Stern HS, Gregoire RC, Kashtan H, Stadler J, Bruce RW. Long-term effects of dietary calcium on risk markers for colon cancer in patients with familial polyposis. Surgery 108 (3):528–33, 1990. | No outcomes of interest
Sugden JA, Davies JI, Witham MD, Morris AD, Struthers AD. Vitamin D improves endothelial function in patients with Type 2 diabetes mellitus and low vitamin D levels. Diabetic Medicine 2008;25:320–5. | >=20% subjects with diseases
Swanenburg J, de Bruin ED, Stauffacher M, Mulder T, Uebelhart D. Effects of exercise and nutrition on postural balance and risk of falling in elderly people with decreased bone mineral density: randomized controlled trial pilot study. Clinical Rehabilitation 2007; 21(6):523–534. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Takeuchi A, Okano T, Tsugawa N et al. Effects of ergocalciferol supplementation on the concentration of Vitamin D and its metabolites in human milk. Journal of Nutrition 119 (11):1639–46, 1989. | Not RCT arrow 4 study
Tanji JL, Lew EY, Wong GY, Treguboff C, Ward JA, Amsterdam EA. Dietary calcium supplementation as a treatment for mild hypertension.. Journal of the American Board of Family Practice 4(3):145–50, 1991. | In systematic review
Taylor EN, Stampfer MJ, Curhan GC. Dietary factors and the risk of incident kidney stones in men: new insights after 14 years of follow-up. Journal of the American Society of Nephrology 15 (12):3225–32, 2004. | No outcomes of interest
Teegarden D, White KM, Lyle RM et al. Calcium and dairy product modulation of lipid utilization and energy expenditure. Obesity 16 (7):1566–72, 2008. | No outcomes of interest
Thompson IM, Coltman CA, Jr., Crowley J. Chemoprevention of prostate cancer: the Prostate Cancer Prevention Trial. Prostate 33 (3):217–21, 1997. | Commentary
Thompson WG, Rostad HN, Janzow DJ, Slezak JM, Morris KL, Zemel MB. Effect of energy-reduced diets high in dairy products and fiber on weight loss in obese adults.. Obesity Research 13(8):1344–53, 2005. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Thomson K, Morley R, Grover SR, Zacharin MR. Postnatal evaluation of Vitamin D and bone health in women who were Vitamin D-deficient in pregnancy, and in their infants.[erratum appears in Med J Aust. 2005 Jan 3;182(1):48 Note: Thompson, Katherine [corrected to Thomson, Katherine]]. Medical Journal of Australia 181 (9):486–8, 2004. | No analysis of association between 25(OH)D and outcomes
Tomoda S, Kitanaka T, Ogita S, Hidaka A. Prevention of pregnancy-induced hypertension by calcium dietary supplement: a preliminary report. Journal of Obstetrics & Gynaecology 21(3):281–8, 1995. | No outcomes of interest
Tretli S, Hernes E, Berg JP, Hestvik UE, Robsahm TE. Association between serum 25(OH)D and death from prostate cancer. British Journal of Cancer 100 (3):450–4, 2009. | >=20% subjects with diseases
Tsang RC, Gigger M, Oh W, Brown DR. Studies in calcium metabolism in infants with intrauterine growth retardation. Journal of Pediatrics 86 (6):936–41, 1975. | No 25(OH)D or dietary Ca
Tworoger SS, Lee IM, Buring JE, Rosner B, Hollis BW, Hankinson SE. Plasma 25-hydroxyVitamin D and 1,25-dihydroxyVitamin D and risk of incident ovarian cancer. Cancer Epidemiology, Biomarkers & Prevention 2007; 16(4):783–788. | No outcomes of interest
van Beresteijn EC, Riedstra M, van der WA, Schouten EG, Burema J, Kok FJ. Habitual dietary calcium intake and blood pressure change around the menopause: a longitudinal study. International Journal of Epidemiology 21(4):683–9, 1992. | No outcomes of interest
van Buul BJ, Steegers EA, Jongsma HW et al. Dietary sodium restriction in the prophylaxis of hypertensive disorders of pregnancy: effects on the intake of other nutrients. American Journal of Clinical Nutrition 62 (1):49–57, 1995. | Ca intake and BM (mothers and neonates) measured but not assessed ==> no relevant results reported
Vatanparast H, Baxter-Jones A, Faulkner RA, Bailey DA, Whiting SJ. Positive effects of vegetable and fruit consumption and calcium intake on bone mineral accrual in boys during growth from childhood to adolescence: the University of Saskatchewan Pediatric Bone Mineral Accrual Study. American Journal of Clinical Nutrition 82 (3):700–6, 2005. | No 25(OH)D or dietary Ca
Vergnaud AC, Peneau S, Chat-Yung S et al. Dairy consumption and 6-y changes in body weight and waist circumference in middle-aged French adults. American Journal of Clinical Nutrition 88 (5):1248–55, 2008. | not RCT (weight outcome)
Verhaar HJ, Samson MM, Jansen PA, de Vreede PL, Manten JW, Duursma SA. Muscle strength, functional mobility and Vitamin D in older women.. Aging-Clinical & Experimental Research 12 (6):455–60, 2000. | In Ottawa EPC report
Verreault R, Semba RD, Volpato S, Ferrucci L, Fried LP, Guralnik JM. Low serum Vitamin d does not predict new disability or loss of muscle strength in older women.. Journal of the American Geriatrics Society 50 (5):912–7, 2002. | In Ottawa EPC report
Verreault R, Semba RD, Volpato S, Ferrucci L, Fried LP, Guralnik JM. Low serum Vitamin d does not predict new disability or loss of muscle strength in older women.. Journal of the American Geriatrics Society 50(5):912–7, 2002. | In Ottawa EPC report
Villar J, bdel-Aleem H, Merialdi M et al. World Health Organization randomized trial of calcium supplementation among low calcium intake pregnant women. American Journal of Obstetrics & Gynecology. 194(3):639–49, 2006 Mar. | In Hofmeyer 2007 systematic review, systematic review
Villar J, Gulmezoglu AM, de OM. Nutritional and antimicrobial interventions to prevent preterm birth: an overview of randomized controlled trials. Obstetrical & Gynecological Survey 53 (9):575–85, 1998 Sep. | Not relevant systematic review
Villar J, Repke JT. Calcium supplementation during pregnancy may reduce preterm delivery in high-risk populations. American Journal of Obstetrics & Gynecology 163 (4 Pt 1):1124–31, 1990. | In Hofmeyer 2007 systematic review
Visser M, Deeg DJ, Lips P, Longitudinal Aging SA. Low Vitamin D and high parathyroid hormone levels as determinants of loss of muscle strength and muscle mass (sarcopenia): the Longitudinal Aging Study Amsterdam. Journal of Clinical Endocrinology & Metabolism 88 (12):5766–72, 2003. | In Ottawa EPC report
von Hurst PR, Stonehouse W, Matthys C, Conlon C, Kruger MC, Coad J. Study protocol--metabolic syndrome, vitamin D and bone status in South Asian women living in Auckland, New Zealand: a randomised, placebo-controlled, double-blind vitamin D intervention. BMC Public Health 8:267, 2008. | RCT protocol only
Wallace K, Baron JA, Cole BF et al. Effect of calcium supplementation on the risk of large bowel polyps.[see comment]. Journal of the National Cancer Institute 96 (12 ):921–5, 2004. | In Weigarten 2008 SR
Wallace K, Baron JA, Karagas MR et al. The association of physical actiVitaminy and body mass index with the risk of large bowel polyps. Cancer Epidemiology, Biomarkers & Prevention 14(9):2082–6, 2005. | No outcomes of interest
Waltman NL, Twiss JJ, Ott CD et al. Testing an intervention for preventing osteoporosis in postmenopausal breast cancer survivors. Journal of Nursing Scholarship 35 (4):333–8, 2003. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Wanchu M, Malhotra S, Khullar M. Calcium supplementation in preeclampsia. Journal of the Association of Physicians of India 49:795–8, 2001. | In Hofmeyer 2007 systematic review
Wang LD, Qiu SL, Yang GR, Lipkin M, Newmark HL, Yang CS. A randomized double-blind intervention study on the effect of calcium supplementation on esophageal precancerous lesions in a high-risk population in China. Cancer Epidemiology, Biomarkers & Prevention 2(1):71–8, 1993. | >=20% subjects with diseases
Wargovich MJ, Isbell G, Shabot M et al. Calcium supplementation decreases rectal epithelial cell proliferation in subjects with sporadic adenoma.. Gastroenterology 103 (1):92–7, 1992. | No outcomes of interest
Webb AR, Pilbeam C, Hanafin N, Holick MF. An evaluation of the relative contributions of exposure to sunlight and of diet to the circulating concentrations of 25-hydroxyVitamin D in an elderly nursing home population in Boston. American Journal of Clinical Nutrition 51 (6):1075–81, 1990. | Not RCT arrow 4 study
Webber CE, Blake JM, Chambers LF, Roberts JG. Effects of 2 years of hormone replacement upon bone mass, serum lipids and lipoproteins. Maturitas. 19(1):13–23, 1994 May. | No 25(OH)D or dietary Ca
Wei EK, Giovannucci E, Fuchs CS, Willett WC, Mantzoros CS. Low plasma adiponectin levels and risk of colorectal cancer in men: a prospective study. Journal of the National Cancer Institute 97 (22):1688–94, 2005. | No 25(OH)D or dietary Ca
Weinberger MH, Wagner UL, Fineberg NS. The blood pressure effects of calcium supplementation in humans of known sodium responsiveness. American Journal of Hypertension 6 (9):799–805, 1993. | In systematic review
Weisgerber UM, Boeing H, Owen RW, Waldherr R, Raedsch R, Wahrendorf J. Effect of longterm placebo controlled calcium supplementation on sigmoidal cell proliferation in patients with sporadic adenomatous polyps. Gut 38 (3):396–402, 1996. | No outcomes of interest
Weisman Y, Bawnik JC, Eisenberg Z, Spirer Z. Vitamin D metabolites in human milk. Journal of Pediatrics 100 (5):745–8, 1982. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Weston TL, Aronson KJ, Siemiatycki J, Howe GR, Nadon L. Cancer mortality among males in relation to exposures assessed through a job-exposure matrix. International Journal of Occupational & Environmental Health 6(3):194–202, 2000. | No 25(OH)D or dietary Ca
Widga AC, Lewis NM. Defined, in-home, prenatal nutrition intervention for low-income women. Journal of the American Dietetic Association 99(9):1058–62, 1999. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Willett WC, Stampfer MJ, Colditz GA, Rosner BA, Speizer FE. Relation of meat, fat, and fiber intake to the risk of colon cancer in a prospective study among women. N Engl J Med 1990; 323(24):1664–1672. | No 25(OH)D or dietary Ca
Williams CP, Child DF, Hudson PR et al. Why oral calcium supplements may reduce renal stone disease: report of a clinical pilot study. Journal of Clinical Pathology 54 (1):54–62, 2001. | No UL outcomes
Wimalawansa SJ. Antihypertensive effects of oral calcium supplementation may be mediated through the potent vasodilator CGRP. American Journal of Hypertension 6 (12):996–1002, 1993. | n=8, Ca to Rx HTN
Witteman JC, Willett WC, Stampfer MJ et al. A prospective study of nutritional factors and hypertension among US women. Circulation 80 (5):1320–7, 1989. | Superceded by Ascherio (4022)
Wortsman J, Matsuoka LY, Chen TC, Lu Z, Holick MF. Decreased bioavailability of Vitamin D in obesity. [erratum appears in Am J Clin Nutr. 2003 May;77(5):1342]. American Journal of Clinical Nutrition 72 (3):690–3, 2000. | Not RCT arrow 4 study
Wosje KS, Kalkwarf HJ. Lactation, weaning, and calcium supplementation: effects on body composition in postpartum women. American Journal of Clinical Nutrition 80 (2):423–9, 2004. | No outcomes of interest
Wyatt HR, Jortberg BT, Babbel C et al. Weight loss in a community initiative that promotes decreased energy intake and increased physical actiVitaminy and dairy consumption: Calcium Weighs-In. Journal of Physical ActiVitaminy & Health 5(1):28–44, 2008. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Yang YX, Han JH, Shao XP et al. Effect of micronutrient supplementation on the growth of preschool children in China. Biomedical & Environmental Sciences 15 (3):196–202, 2002. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Yesudian PD, Berry JL, Wiles S et al. The effect of ultraviolet B-induced Vitamin D levels on host resistance to Mycobacterium tuberculosis: a pilot study in immigrant Asian adults living in the United Kingdom. Photodermatology, Photoimmunology & Photomedicine 24 (2):97–8, 2008. | No outcomes of interest
Zemel MB, Richards J, Milstead A, Campbell P. Effects of calcium and dairy on body composition and weight loss in African-American adults. Obesity Research 13(7):1218–25, 2005. | In systematic review
Zemel MB, Thompson W, Milstead A, Morris K, Campbell P. Calcium and dairy acceleration of weight and fat loss during energy restriction in obese adults.. Obesity Research 12 (4):582–90, 2004. | In systematic review
Zhang Y, Kiel DP, Ellison RC et al. Bone mass and the risk of prostate cancer: the Framingham Study. American Journal of Medicine 113 (9):734–9, 2002. | No 25(OH)D or dietary Ca
Zhou C, Fan S, Zhou L, Ni Y, Huang T, Shi Y. Clinical observation of treatment of hypertension with calcium. American Journal of Hypertension 7 (4 Pt 1):363–7, 1994. | In systematic review
Zofkova I, Hill M. Long-term 1,25(OH)2 Vitamin D therapy increases bone mineral density in osteopenic women. Comparison with the effect of plain Vitamin D. Aging-Clinical & Experimental Research. 19(6):472–7, 2007 Dec. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Zorbas YG, Petrov KL, Kakurin VJ et al. Calcium supplementation effect on calcium balance in endurance-trained athletes during prolonged hypokinesia and ambulatory conditions. Biological Trace Element Research 73 (3):231–50, 2000. | Arrow 4: calcium balance