# Evaluation of existing systematic reviews and evidence tables of the qualified systematic reviews

Evaluation of existing systematic reviews

Author Year Journal/Source | Intervention or exposure | Outcome | Study design included | Healthy population at baseline?^*^ | Only included Ca +− Vit D interventions? ** Reported baseline dietary Ca intake with dietary assessment methods?^***^ | Clear reporting of comparison and control group? | Clear reporting of outcome definitions? | Clear reporting of study designs (need separate reporting if two or more different designs are included)? | Comments^****^
Autier 2007 Arch Intern Med [17846391]1 | Vitamin D [+/− Calcium] | All cause mortality | RCTs | Yes1 | Yes | Yes | Yes | Yes | One additional study found
Avenell 2008 Cochrane Database of Systematic Reviews [16034849]2 | Vitamin D [+/− Calcium] | All cause mortality | RCTs | Yes | Yes | Yes | Yes | Yes | All relevant studies included in Autier 2007 – Conclusions are same as Autier 2007.
Allender 1996 Ann Intern Med | Ca supplement | Blood pressure | RCT | Yes (subgroup analysis) | Yes | Yes | Yes | Yes | 26 of 64 potential RCTs
Cappuccio 1995 AJE | Ca intake | Blood pressure | Observational, including cross- sectional | Unclear | No | NA (regressions) | Yes | No | REJECT Includes XS
Dickinson 2008 Cochrane | Ca supplement | Blood pressure | RCT | No All with HTN | Yes | Yes | Yes | Yes | Revision of 2006 SR 15/64 potential RCTs
Griffith 1999 AJH | Ca supplement | Blood pressure | RCT | Yes & No HTN & NTN combined See comment | Yes | Yes | Yes | Yes | Update of Bucher 1996 [2263] Subgp analysis HTN vs NTN in Bucher only 42/64 potential RCTs
van Mierlo 2006 J Hum Hypert | Ca supplement | Blood pressure | RCT | Yes Subgroup of HTN & NTN | Yes | Yes | Yes | Yes | 40/64 potential RCTs
Trumbo 2007 Nutr Rev | Ca supplement | Blood pressure, HTN, Pregnancy-induced HTN | All | Yes Subgroup of HTN & NTN | Yes (interv) No (observ) | No | No | No | REJECT Qualitative only Count of sig studies only Unclear if SR.
Bergsma-Kadijk1996 Epidemiology | Ca intake | cancer and polyp | Cohort and Case-control | nd (probably healthy population) | nd on dietary assessment method | nd on Ca intake (only RR/OR between lowest and highest categories reported) | nd | nd on the definition of case-control study | Reject
Weigarten 2008 Cochrane Database of Systematic Reviews | Ca supplement (>1200 mg/d) | cancer and polyp | RCT | yes (pts with prior adenoma) | yes | yes | yes | yes | Accept
Davies 2006 J Natl Cancer Inst | Nutritional RCTs, including Ca supplement | Cancer, recurrence of preinvasive lesions | RCT | No (both pts with cancer and preinvasive lesions) | nd | no | no | yes | Part of a larger SR of both diet and physical activity on outcome among patients with cancer or preinvasive lesions
Bergel 2007 BMC Pediatrics | maternal calcium intake | offspring BP | RCTs & cohort | y (RCT) | no yes | yes | yes | no | Data from 2 RCTs may be useful. Reject
Carroli 1994 Brit J Obstet Gynecol | Ca supplement | Preeclampsia | RCT | Yes | Yes | Yes | Yes | Yes | Covered by latest Cochrane SR
Hofmeyer 2003 S African J | Ca Supplement | Preeclampsia | RCT | Yes | Yes | Yes | Yes | Yes | Covered by latest Cochrane SR
Hofmeyer 2007 S African J | Ca Supplement | Preeclampsia(and summary of the outcomes mentioned above) | RCT | Yes | Yes | Yes | Yes | Yes | Covered by latest Cochrane SR
Hoffmeyr 2006 Cochrane Database of Systematic Reviews | Ca supplement | Preeclampsia, pregnancy induced hypertension with and without proteinuria, maternal death or serious morbidity, other maternal outcomes, stillbirth, neonatal mortality or morbidity, preterm birth, small gestational age, and other outcomes for the child | RCT | Yes | Yes | Yes | Yes | Yes | Eligible review
Bucher 1996 JAMA | Ca supplement | Preeclampsia, pregnancy-induced hypertension | RCT | Yes | Yes | Yes | Yes | Yes | Covered by latest Cochrane SR
Gao 2005 NCI | calcium intake or dairy product | prostate cancer | prospective cohort | yes (assumed from study design) | yes | yes | yes | yes
Shaukat 2005 Am J Gastroenterol | Ca supplement | recurrent polyp | RCT | yes (pts with prior adenoma) | no (1/3 included Ca+Vit A/C/E+selenium) | yes | yes? “recurrence of adenoma” | yes? “RCT” | Reject
Barr 2003 J Nutr | Increased dairy product or calcium intake (from supplements) | Weight | RCTs | Yes “healthy” | Yes (separate studies of increased dairy product and those of calcium supplements) | yes | yes | yes | No meta-analysis. Included children and adults
Trowman 2006 Br J Nutr | Calcium supplements or increased provision of dairy products | Weight | RCTs | Yes (excluded populations with severe co-morbidities, such as renal problems or cancer) | Yes (Separate meta-analyses for calcium supplement and increased provision of dairy products) | yes | yes | yes | May need to redo the meta-analyses to separate out energy restriction diet studies. This SR included adults only.
Winzenberg 2007 Obesity | calcium supplementation food or chemical | weight | RCTs | yes | yes | yes | yes | yes | 2° analysis of RCT of calcium on bone density outcome
Lanou 2008 Nutr Rev | Calcium or dairy supplementation with or without energy restriction | Weight, body fat | RCTs | nd | yes | no | yes | yes | Included both dairy and calcium supplementation RCTs. No individual study characteristics reported

* Either included only healthy population at baseline or SR had separate analyses for population with diseases and without diseases

** For SR of interventional studies

*** For SR of observational studies

**** Please comment on issues such as update of previous SRs or specific reasons for using or not using the SR, other than not fulfilling the screening criteria.

Evidence table of systematic review of the effect of vitamin D on bone health

Author Year [PMID] | Cranney 2007 [18088161]
Design | Systematic review of RCTs and observational studies
Population | - Include all ages; - Exclude secondary causes of osteoporosis (e.g., glucocorticoid-induced, renal or liver disease); - Exclude studies on the treatment of vitamin D-dependent rickets (to minimize clinical heterogeneity as treatments is often non-dietary sources of vitamin D)
Intervention (Exposure) and Comparator | Intervention (Exposure):; - Include vitamin D_2_ or D_3_ with or without calcium.; - Exclude vitamin D preparations, calcitriol, alphacalcidol (because they are not nutritional supplements, and have different safety profile); Comparator:; - No vitamin D or lower doses/levels of vitamin D
Results | See text for summary results for the following outcomes in both vitamin D and combined vitamin D and calcium sections of the report:; - Rickets; - Fractures, falls, or performance measures; - Bone mineral density or bone mineral contents; - How does dietary intake of vitamin D from fortified foods and vitamin D supplementation affect serum 25(OH)D Concentrations; - Adverse events
Comments | Case-control studies were included but always summarized separately from cohort studies and RCTs. Meta-analyses were performed to pool results from RCTs only.
AMSTAR
A priori design? | Yes | Study quality assessment performed? | Yes
Two independent reviewers? | Yes | Study quality appropriately used in analysis? | Yes
Comprehensive literature search? | Yes | Appropriate statistical synthesis? | Yes
All publication types and languages included? | No | Publication bias assessed? | No
Included and excluded studies listed? | Yes | Conflicts of interest stated? | Yes
Study characteristics provided? | Yes

Evidence table of systematic review on vitamin D supplementation and all-cause mortality

Author Year [PMID] | Autier 2007 [17846391]
Design (Search Years) | Randomized controlled trials (1992–2006)
Population | Community dwelling or institutionalized adults
Intervention (Exposure) and Comparator | Supplementary vitamin D (at least 1000 mg/d) without calcium vs. placebo or no treatment
Results | 18 trials of combined vitamin D and vitamin D + calcium RR: 0.93 (95% CI 0.87, 0.99); favoring vitamin D (± calcium) supplementation Statistically homogeneous In our reanalysis we and excluded 3 of 18 trials and separated studies with vitamin D only from those with vitamin D and calcium combination. For details and results of our reanalysis, see text.
Comments | See text in vitamin D and vitamin D + calcium sections for reanalyses of the separated trials. Study participants, vitamin D assays, and vitamin D status are not described in detail.
AMSTAR Criteria
A priori design? | Yes | Study quality assessment performed? | No
Two independent reviewers? | No | Study quality appropriately used in analysis? | NA
Comprehensive literature search? | Yes | Appropriate statistical synthesis? | Yes
All publication types and languages included? | Yes | Publication bias assessed? | No
Included and excluded studies listed? | No | Conflicts of interest stated? | Yes
Study characteristics provided? | Yes | The meta-analysis did not perform quality assessment (neither using individual quality items nor using quality scores)

Evidence table of systematic review of calcium on growth in children

Author Year [PMID] | Winzenberg 2007 [17636098]
Design (Search Years) | Randomized controlled trials (1966–2005)
Population | Children <18 y
Intervention (Exposure) and Comparator | Supplemental and dietary calcium 300–1200 mg/d vs. placebo
Results | 17 trials (2088 participants) Weighted mean difference: +0.14 (95% CI −0.28, +0.57) Kg; favors control Weighted mean difference: +0.22 (95% CI −0.30, +0.74) cm; favors control No significant statistical heterogeneity
Comments | Post hoc analysis performed on trials identified for a metaanalysis of randomized controlled trials of calcium on bone outcomes
AMSTAR
A priori design? | Yes | Study quality assessment performed? | Yes
Two independent reviewers? | Yes | Study quality appropriately used in analysis? | No
Comprehensive literature search? | Yes | Appropriate statistical synthesis? | Yes
All publication types and languages included? | No | Publication bias assessed? | Yes
Included and excluded studies listed? | No | Conflicts of interest stated? | No
Study characteristics provided? | Yes | Unclear if all languages included; study quality assessed but not factored into the M-A

Evidence table of systematic review s of calcium and blood pressure

Author Year [PMID] | Griffith 1999 [10075392]
Design (Search Years) | Randomized controlled trials (1966–1997)
Population | Both hypertensive and normotensive participants
Intervention and Comparator | Dietary and nondietary calcium supplementation versus placebo (no supplement) Dose range 600–2000 mg (36% 1000 mg; 26% 1500–1600 mg; 12% 2000 mg)
Results | 42 trials SBP: −1.44 (−2.20, −0.68)2; statistically heterogeneous DBP: −0.84 (−1.44, −0.24); statistically heterogeneous Subgroup analyses did not find that heterogeneity could be explained by age, sex, baseline calcium, dietary versus nondietary calcium, or quality. Subgroups with hypertensive versus normotensive people were significantly different (no further details). Conclusions similar to previous systematic review (Bucher 1996{2263/id})
Comments | Update of Bucher 1996{2263/id} (see below).
AMSTAR
A priori design? | Yes | | Study quality assessment performed? | Yes
Two independent reviewers? | Yes | | Study quality appropriately used in analysis? | No
Comprehensive literature search? | Yes | | Appropriate statistical synthesis? | Yes
All publication types and languages included? | Yes | | Publication bias assessed? | No
Included and excluded studies listed? | Yes | | Conflicts of interest stated? | No
Study characteristics provided? | Yes | | Study quality not discussed in conclusions. Funding source reported, but not conflict of interest.
Author Year [PMID] | van Mierlo 2006 [16673011]
Design (Search Years) | Randomized controlled trials (1966–2003)
Population | Both hypertensive and normotensive participants
Intervention and Comparator | Calcium supplementation versus placebo (no supplement) Dose range 355–2000 mg (40% 1000 mg; 32% 1500–1600 mg; 6% 2000 mg)
Results | 40 trials SBP: −1.86 (95% CI −2.91, −0.81); statistically heterogeneous DBP: −0.99 (95% CI −1.61, −0.37); statistically heterogeneous In multivariable analysis including age, sex, initial calcium intake, calcium dose, and initial blood pressure:
Results | | | SBP | DBP
Results | Age | <45 y | −1.45 (−2.99, +0.09) | −1.26 (−2.20, −0.33)
Results | | ≥45 y | −2.33 (−3.69, −0.96) | −0.80 (−1.62, +0.02)
Results | Male | ≤50% | −2.20 (−3.68, −0.72) | −1.12 (−1.98, −0.26)
Results | | >50% | −1.77 (−3.13, −0.42) | −0.84 (−1.65, −0.04)
Results | Initial BP | <140/90 mm Hg | −2.04 (−3.40, −0.68) | −1.04 (−1.86, −0.22)
Results | | ≥140/90 mm Hg | −1.85 (−3.45, −0.32) | −0.89 (−1.79, +0.01)
Results | Ca dose | ≤1000 mg | −2.17 (−3.59, −0.75) | −1.41 (−2.24, −0.59)
Results | | >1000 mg | −1.75 (−3.20, −0.31) | −0.56 (−1.40, +0.29)
Results | Blood pressures not statistically significantly different between any strata.
Comments
AMSTAR
A priori design? | Yes | | Study quality assessment performed? | Yes
Two independent reviewers? | Yes | | Study quality appropriately used in analysis? | No
Comprehensive literature search? | Yes | | Appropriate statistical synthesis? | Yes
All publication types and languages included? | Unclear | | Publication bias assessed? | Yes
Included and excluded studies listed? | Partial | | Conflicts of interest stated? | Yes
Study characteristics provided? | Yes | | No data on inclusion of unpublished data. Excluded studies available from authors
Author Year [PMID] | Bucher 1996 [8596234]
Design (Search Years) | Randomized controlled trials (1966–1994)
Population | Both hypertensive and normotensive participants
Intervention and Comparator | Dietary and nondietary calcium supplementation versus placebo (no supplement) Dose range 406–2000 mg (41% 1000 mg; 31% 1500–1600 mg; 8% 2000 mg)
Results | 33 trials [Overall summary results were updated in Griffith 1999{1927/id}, above] Studies with specified subgroups of hypertensive and normotensive participants (6 trials):
Results | Hypertensives | | SBP −4.30 (−6.47, −2.13) | DBP −1.50 (−2.77, −0.23)
Results | Normotensives | | SBP −0.27 (−1.80, +1.27) | DBP −0.33 (−1.56, +0.90)
Results | Regression analyses:
Results | BP (continuous scale) | | SBP OR = 0.99 (0.96, 1.01) | DBP OR = 0.99 (0.96, 1.03)
Results | Dose of calcium, duration of supplementation, dietary vs nondietary calcium supplementation, methodological quality did not demonstrate a relationship with the magnitude of treatment effect.
Comments | Updated in Griffith 1999{1927/id} (see above)
AMSTAR
A priori design? | Yes | | Study quality assessment performed? | Yes
Two independent reviewers? | Yes | | Study quality appropriately used in analysis? | Yes
Comprehensive literature search? | Yes | | Appropriate statistical synthesis? | Yes
All publication types and languages included? | Yes | | Publication bias assessed? | No
Included and excluded studies listed? | Yes | | Conflicts of interest stated? | No
Study characteristics provided? | Yes | | Funding source reported, but not conflict of interest.
Author Year [PMID] | Allender 1996 [8610952]
Design (Search Years) | Randomized controlled trials (1982–1993)
Population | Both hypertensive and normotensive participants
Intervention and Comparator | Dietary and nondietary calcium supplementation versus placebo (no supplement) Dose range 400–2160 mg (35% 1000 mg; 29% 1500–1600 mg; 10% 2000 mg)
Results | 26 trials (22 trials included in metaanalyses) SBP: −0.89 (−1.74, −0.05) DBP: −0.18 (−0.75, +0.40)
Results | Hypertensivess | | SBP −1.68 (−3.18, −0.18) | DBP +0.02 (−0.96, +1.00)
Results | Normotensives | | SBP −0.53 (−1.56, +0.49) | DBP −0.28 (−0.99, +0.42)
Results | By weighted linear regression analyses, age, sex, calcium dose, trial duration were not associated with treatment effect (P>0.10)
Comments
AMSTAR
A priori design? | Yes | | Study quality assessment performed? | No
Two insdependent reviewers? | Yes | | Study quality appropriately used in analysis? | No
Comprehensive literature search? | Yes | | Appropriate statistical synthesis? | No
All publication types and languages included? | Yes | | Publication bias assessed? | No
Included and excluded studies listed? | No | | Conflicts of interest stated? | No
Study characteristics provided? | Yes | | Excluded studies not enumerated or listed. Fixed effects models used.
Author Year [PMID] | Cappuccio 1989 [2697729]
Design (Search Years) | Randomized controlled trials (1983–1988)
Population | Both hypertensive and normotensive participants
Intervention and Comparator | Nondietary calcium supplementation versus placebo (no supplement) or low calcium intake Dose range 800–1600 mg (60% 1000 mg; 27% 1500–1600 mg)
Results | 15 trials SBP (supine): −0.13 (−0.46, +0.19) DBP (supine): +0.03 (−0.17, +0.22)
Results | Hypertensives | | SBP +0.06 (−0.59, +0.72) | DBP +0.03 (−0.21, +0.27)
Comments
AMSTAR
A priori design? | Yes | | Study quality assessment performed? | No
Two independent reviewers? | Nd | | Study quality appropriately used in analysis? | NA
Comprehensive literature search? | Yes | | Appropriate statistical synthesis? | No
All publication types and languages included? | nd | | Publication bias assessed? | No
Included and excluded studies listed? | No | | Conflicts of interest stated? | No
Study characteristics provided? | Yes | | Excluded studies not enumerated or listed. Fixed effects models used.
Author Year [PMID] | Dickinson 2006 [16625609]3; 3 A technical update, with no further studies added was published in the Cochrane database in 2008
Design (Search Years) | Randomized controlled trials (1982–2003/20054; 4 Different dates for different databases.; )
Population | Hypertensive participants
Intervention and Comparator | Dietary and nondietary calcium supplementation versus placebo (no supplement) Dose range 400–2000 mg (50% 1000 mg; 25% 1500–1600 mg; 6% 2000 mg)
Results | 13 trials SBP: −2.53 (−4.45, −0.60); statistically heterogeneous DBP: −0.81 (−2.07, +0.44); statistically heterogeneous
Results | Ca dose <1200 mg | | SBP −2.67 (−5.15, −0.18) | DBP −0.75 (−2.13, +0.63)
Results | Ca dose 1200–2000 mg | | SBP −2.69 (−5.86, +0.47) | DBP −0.78 (−3.82, +2.25)
Results | Not statistically significantly different by calcium dose
Comments
AMSTAR
A priori design? | Yes | | Study quality assessment performed? | Yes
Two independent reviewers? | Yes | | Study quality appropriately used in analysis? | Yes
Comprehensive literature search? | Yes | | Appropriate statistical synthesis? | Yes
All publication types and languages included? | Yes | | Publication bias assessed? | Yes
Included and excluded studies listed? | Yes | | Conflicts of interest stated? | Yes
Study characteristics provided? | Yes

Evidence table of systematic review of calcium on growth in children

Author Year [PMID] | Winzenberg 2007 [17636098]
Design (Search Years) | Randomized controlled trials (1966–2005)
Population | Children <18 y
Intervention (Exposure) and Comparator | Supplemental and dietary calcium 300–1200 mg/d vs. placebo
Results | 17 trials (2088 participants) Weighted mean difference: +0.14 (95% CI −0.28, +0.57) Kg; favors control Weighted mean difference: +0.22 (95% CI −0.30, +0.74) cm; favors control No significant statistical heterogeneity
Comments | Post hoc analysis performed on trials identified for a metaanalysis of randomized controlled trials of calcium on bone outcomes
AMSTAR
A priori design? | Yes | Study quality assessment performed? | Yes
Two independent reviewers? | Yes | Study quality appropriately used in analysis? | No
Comprehensive literature search? | Yes | Appropriate statistical synthesis? | Yes
All publication types and languages included? | No | Publication bias assessed? | Yes
Included and excluded studies listed? | No | Conflicts of interest stated? | No
Study characteristics provided? | Yes | Unclear if all languages included; study quality assessed but not factored into the M-A

Evidence table of systematic review on calcium intake and adenoma recurrence

Author Year [UI] | Weingarten, 2008 [18254022]
Design | Randomized controlled trials: Cochrane Library Issue 2, 2007, the Cochrane Colorectal Cancer Group (CCCG) specialized register, MEDLINE (1966 to July 2007), Cancerlit (1963 to April 2002), Embase (1980 to July 2007)
Population | Healthy adults and studies of adults at higher risk of colon cancer due to family history, previous adenomatous polyps, or inflammatory bowel disease
Intervention (Exposure) and Comparator | Calcium (>1200 mg/d) vs. placebo
Results | Calcium vs. placebo colorectal adenoma recurrence: OR 0.74, CI 0.58–0.95, P=0.02 CRC: OR 0.34, CI 0.05–2.15, P=0.20 at least one adverse event requiring discontinuation: OR 0.93, CI 0.42–2.05, P=0.80
Comments | Based only on two RCTs (1346 participants). Heterogeneity due to different dose of supplementation (one RCT supplemented with 1200 mg/d and the other RCT with 2000 mg/d). Analysis based on fixed effects model; however, considering there are only two studies, random effects model might have been more appropriate. Analysis on adverse events is based only on reported data of one out of the two RCTs (Barron 1999). Only participants with high risk due to previous adenomas were recruited in these two RCTs; therefore, applicability of the results can only be considered for high risk population. Insufficient evidence to recommend the general use of calcium supplements to prevent colorectal adenoma or colorectal cancer
AMSTAR
A priori design? | X | Study quality assessment performed? | X
Two independent reviewers? | X | Study quality appropriately used in analysis? | X
Comprehensive literature search? | X | Appropriate statistical synthesis? | X
All publication types and languages included? | | Publication bias assessed?
Included and excluded studies listed? | X | Conflicts of interest stated? | X
Study characteristics provided? | X