# Search strategy for primary studies

## a Overall Search Strategy for Outcomes of Estimated Average Requirements

Database: Ovid MEDLINE(R), CCTR (1969 to April 2009)

1. exp Vitamin D/
2. (25-hydroxy vit D or plasma vit D or 25OHD or 25-OHD).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
3. (25OHD3 or “25(OH)D3” or 25-OHD3 or “25-(OH)D3”).tw.
4. (“25(OH)D” or “25-(OH)D” or “25-OH-D”).tw.
5. 25-hydroxycholecalciferol.tw.
6. 25-hydroxyergocalciferol.tw.
7. calcidiol.tw.
8. Calcifediol/
9. (vit adj (d or d2 or d3)).mp.
10. Ergocalciferols/
11. Ergocalciferol$.tw.
12. Cholecalciferol/
13. Cholecalciferol$.tw.
14. calciferol.tw.
15. or/1–14
16. exp Calcium/
17. exp Calcium Carbonate/or exp Calcium Citrate/or exp Calcium Phosphates/or exp Calcium Malate/
18. exp Calcium, Dietary/
19. calcium.tw.
20. or/16–19
21. (ANIMALS not HUMAN).sh.
22. *Dialysis/or *hemodialysis/or *peritoneal dialysis/
23. 15 or 20
24. 23 not 21
25. 24 not 22
26. limit 25 to (addresses or bibliography or biography or comment or congresses or consensus development conference or consensus development conference, nih or dictionary or directory or duplicate publication or editorial or in vitro or interview or lectures or letter or news or newspaper article or “review”)
27. 25 not 26
28. limit 27 to english language
29. randomized controlled trial.pt.
30. controlled clinical trial.pt.
31. randomized controlled trials/
32. Random Allocation/
33. Double-blind Method/
34. Single-Blind Method/
35. clinical trial.pt.
36. Clinical Trials.mp. or exp Clinical Trials/
37. (clinic$ adj25 trial$).tw.
38. ((singl$ or doubl$ or trebl$ or tripl$) adj (mask$ or blind$)).tw.
39. Placebos/
40. placebo$.tw.
41. random$.tw.
42. trial$.tw.
43. (latin adj square).tw.
44. Comparative Study.tw.
45. exp Evaluation studies/
46. Follow-Up Studies/
47. Prospective Studies/
48. (control$ or prospectiv$ or volunteer$).tw.
49. Cross-Over Studies/
50. or/29–49
51. 50 and 28
52. 28 not 51
53. limit 51 to yr=“1969–2008”
54. limit 52 to yr=“1969–2008”
55. 53 not (“200810$” or “200811$” or “200812$”).ed.
56. 54 not (“200810$” or “200811$” or “200812$”).ed.
57. 55 or 56
58. exp Vitamin D/
59. (25-hydroxy vit D or plasma vit D or 25OHD or 25-OHD).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
60. (25OHD3 or “25(OH)D3” or 25-OHD3 or “25-(OH)D3”).tw.
61. (“25(OH)D” or “25-(OH)D” or “25-OH-D”).tw.
62. 25-hydroxycholecalciferol.tw.
63. 25-hydroxyergocalciferol.tw.
64. calcidiol.tw.
65. Calcifediol/
66. (vit adj (d or d2 or d3)).mp.
67. Ergocalciferols/
68. Ergocalciferol$.tw.
69. Cholecalciferol/
70. Cholecalciferol$.tw.
71. calciferol.tw.
72. or/58–71
73. exp Calcium/
74. exp Calcium Carbonate/or exp Calcium Citrate/or exp Calcium Phosphates/or exp Calcium Malate/
75. exp Calcium, Dietary/
76. calcium.tw.
77. or/73–76
78. (ANIMALS not HUMAN).sh.
79. (ANIMALS not HUMAN).sh.
80. 72 or 77
81. 80 not 78
82. 81 not 79
83. limit 82 to (addresses or bibliography or biography or comment or congresses or consensus development conference or consensus development conference, nih or dictionary or directory or duplicate publication or editorial or in vitro or interview or lectures or letter or news or newspaper article or “review”)
84. 82 not 83
85. limit 84 to english language
86. randomized controlled trial.pt.
87. controlled clinical trial.pt.
88. randomized controlled trials/
89. Random Allocation/
90. Double-blind Method/
91. Single-Blind Method/
92. clinical trial.pt.
93. Clinical Trials.mp. or exp Clinical Trials/
94. (clinic$ adj25 trial$).tw.
95. ((singl$ or doubl$ or trebl$ or tripl$) adj (mask$ or blind$)).tw.
96. Placebos/
97. placebo$.tw.
98. random$.tw.
99. trial$.tw.
100. (latin adj square).tw.
101. Comparative Study.tw.
102. exp Evaluation studies/
103. Follow-Up Studies/
104. Prospective Studies/
105. (control$ or prospectiv$ or volunteer$).tw.
106. Cross-Over Studies/
107. or/86–106
108. 107 and 85
109. 85 not 108
110. limit 108 to yr=“1969–2008”
111. limit 109 to yr=“1969–2008”
112. 110 not (“200810$” or “200811$” or “200812$”).ed.
113. 111 not (“200810$” or “200811$” or “200812$”).ed.
114. 112 or 113
115. verapamil.mp. or 52–53–9.rn.
116. nifedipine.mp. or 21829-25-4.rn.
117. diltiazem.mp. or 42399-41–7.rn.
118. Azelnidipine.mp. or 123524–52–7.rn.
119. nicardipine.mp. or 55985-32–5.rn.
120. felodipine.mp. or 72509–76-3.rn.
121. mepirodipine.mp. or 104713–75–9.rn.
122. Amlodipine.mp. or 88150-42–9.rn.
123. isradipine.mp. or 75695-93-1.rn.
124. bepridil.mp. or 64706–54-3.rn.
125. gallopamil.mp. or 16662-47–8.rn.
126. aranidipine.mp. or 86780–90–7.rn.
127. nitrendipine.mp. or 39562–70–4.rn.
128. Barnidipine.mp.
129. benidipine.mp. or 105979-17-7.rn.
130. Cilnidipine.mp. or 132203–70–4.rn.
131. clevidipine.mp.
132. efonidipine.mp. or 111011–53-1.rn.
133. Lacidipine.mp. or 103890-78-4.rn.
134. Lercanidipine.mp. or 100427-26–7.rn.
135. Manidipine.mp. or 89226–50–6.rn.
136. Nilvadipine.mp. or 75530–68-6.rn.
137. Nimodipine.mp. or 66085-59-4.rn.
138. Nisoldipine.mp. or 63675-72–9.rn.
139. Pranidipine.mp. or 99522–79-9.rn.
140. ((calcium or Ca) adj3 channel$).mp.
141. ((calcium or Ca) adj3 agonist$).mp.
142. (intracellular adj2 (calcium or Ca)).mp.
143. or/115–142
144. weight loss.mp. or exp Weight Loss/
145. body mass index.mp. or exp Body Mass Index/or exp Body Mass/or body mass.mp. or exp body weight/or body weight.mp.
146. 144 or 145
147. obesity.mp. or exp OBESITY/pc, di, ep, et
148. or/144–147
149. limit 148 to (“all infant (birth to 23 months)” or “newborn infant (birth to 1 month)” or “infant (1 to 23 months)” or “preschool child (2 to 5 years)”)
150. limit 149 to (“all adult (19 plus years)” or “child (6 to 12 years)” or “adolescent (13 to 18 years)” or “adult (19 to 44 years)” or “middle age (45 to 64 years)” or “middle aged (45 plus years)” or “all aged (65 and over)” or “aged (80 and over)”)
151. 149 not 150
152. 148 not 151
153. exp Body Height/
154. exp body size/
155. growth velocity.af.
156. growth retardation.af.
157. growth delay.af.
158. growth restriction.af.
159. (height adj6 restrict$).af.
160. linear velocity.af.
161. (height adj6 delay).af.
162. length delay.af.
163. (length adj6 retardation).af.
164. or/153–163
165. limit 164 to (“all infant (birth to 23 months)” or “all child (0 to 18 years)” or “newborn infant (birth to 1 month)” or “infant (1 to 23 months)” or “preschool child (2 to 5 years)” or “child (6 to 12 years)” or “adolescent (13 to 18 years)”)
166. 164 not 165
167. limit 166 to (“all adult (19 plus years)” or “adult (19 to 44 years)” or “middle age (45 to 64 years)” or “middle aged (45 plus years)” or “all aged (65 and over)” or “aged (80 and over)”)
168. 164 not 167
169. Bone Density/
170. exp Osteoporosis/
171. ((bone$ or plate$) adj3 mineral$).tw.
172. (bone adj2 (loss or turnover or densi$)).tw.
173. (Skelet$ adj2 (mineral$ or development$)).tw.
174. mineralization defect$.tw.
175. Mineral$ content$.tw.
176. BMC.tw.
177. Osteoporo$.tw.
178. Osteomalac$.tw.
179. Osteopath$.tw.
180. Bone Development/
181. Osteogenesis/
182. fracture$.tw.
183. Accidental Falls/
184. falls.tw.
185. exp “Bone and Bones”/
186. or/169–185
187. Rickets/
188. rachitis.tw.
189. rickets.tw.
190. or/187–189
191. tooth loss.mp. or exp Tooth Loss/
192. 190 or 186 or 191
193. limit 192 to yr=“2006–2008”
194. exp Cardiovascular Diseases/pc, di, ep, et
195. Cardi$.mp.
196. 195
197. Coronary.mp.
198. heart disease$.mp.
199. Myocardial infarct$.mp.
200. exp Cerebrovascular Accident/
201. stroke.tw.
202. Transient Ischemic Attack.tw.
203. exp Ischemia/
204. cardioprotect$.mp.
205. Pulmonary Embol$.tw.
206. Heart failure$.tw.
207. (embol$ or thromb$).tw.
208. exp Peripheral Vascular Diseases/or peripheral artery disease.mp.
209. arterial occlusive diseases/
210. or/194–209
211. limit 210 to “all adult (19 plus years)”
212. exp hypertension/pc, di, ep, et
213. exp hypertension, renal/
214. hypertens$.af.
215. high blood pressure.af.
216. (eleva$ adj2 blood pressure).tw.
217. systolic blood pressure/
218. diastolic blood pressure/
219. mean arterial pressure/
220. or/212–219
221. limit 220 to “all adult (19 plus years)”
222. exp Neoplasms/dh, pc, et, di, ep [Diet Therapy, Prevention & Control, Etiology, Diagnosis, Epidemiology]
223. (“cancer risk” or “melanoma risk” or “lymphoma risk” or “leukemia risk” or “myeloma risk” or “sarcoma risk”).tw.
224. ((“risk of” or “occurrence of”) and (cancer$ or neoplasm$ or malignan$ or adenocarcinom$ or carcinom$ or melanom$ or lymphom$ or leuk?emi$ or myelodysplas$ or myelom$ or sarcom$)).tw.
225. 222 or 224 or 223
226. colon polyps.mp. or exp adenomatous polyps/or exp colonic polyps/
227. (colon$ or rectum or rectal or colorectum or colorectal).ti, ab.
228. (adenoma$ or polyps or polyp).ti, ab.
229. 228 and 227
230. 229 or 226
231. mammography.mp. or exp mammography/
232. mammog$.ti, ab.
233. 231 or 232
234. dens$.ti, ab.
235. 233 and 234
236. prostate specific antigen.mp. or exp prostate-specific antigen/
237. (aberrant crypt$ foc$ or ACF).ti, ab.
238. (prostat$ and (intraepitheli$ or intra-epitheli$ or intra epitheli$) and Neoplas$).ab, ti.
239. 236 or 238 or 235 or 237 or 230
240. type 1 diabetes mellitus.mp. or exp Diabetes Mellitus, Type 1/
241. psoriasis.mp. or exp Psoriasis/
242. rheumatoid arthritis.mp. or exp Arthritis, Rheumatoid/
243. multiple sclerosis.mp. or exp Multiple Sclerosis/
244. inflammatory bowel disease.mp. or exp Inflammatory Bowel Diseases/
245. ulcerative colitis.mp. or exp Colitis, Ulcerative/
246. Crohn’s disease.mp. or exp Crohn Disease/
247. 240 or 241 or 242 or 243 or 244 or 245 or 246
248. tuberculosis.mp. or exp Tuberculosis/
249. influenza.mp. or exp Influenza, Human/
250. 248 or 249
251. exp “Activities of Daily Living”/
252. muscle strength.mp. or exp Muscle Strength/
253. exp Musculoskeletal Equilibrium/or exp Walking/
254. (“balance test” or “timed walk” or “physical performance” or “hand-grip strength”).tw.
255. exp Hand Strength/
256. exp Muscles/
257. (“walking time” or “muscle strength”).tw.
258. or/251–257
259. limit 258 to (“all adult (19 plus years)” or “all aged (65 and over)” or “aged (80 and over)”)
260. exp Pre-eclampsia/
261. (pre-eclampsia or preeclampsia).mp.
262. pregnancy complication$.mp. or exp Pregnancy Complications/
263. or/260–262
264. limit 263 to male
265. limit 263 to female
266. 264 not 265
267. 263 not 266
268. limit 267 to animal
269. limit 267 to human
270. 268 not 269
271. 267 not 270
272. limit 271 to english language
273. exp infant, low birth weight/
274. low birth weight.af.
275. exp infant, premature/
276. (“small for gestational age” or sga).af.
277. ((preterm or prematur$) adj6 (infant or newborn)).af.
278. or/273–277
279. exp Milk, Human/
280. human milk.mp.
281. (human adj2 milk).tw.
282. breast milk.mp.
283. breastmilk.mp.
284. breast feeding.mp.
285. breastfeed$.mp.
286. breast fed.mp.
287. breastfed.mp.
288. (breast adj2 fed).tw.
289. exp lactation/
290. (lactating or lactation).mp.
291. or/279–290
292. Mortality.mp. or exp Mortality/
293. Fatal Outcome.mp. or exp Fatal Outcome/
294. exp Death/or exp “Cause of Death”/or death.mp.
295. Survival Rate.mp. or exp Survival Rate/
296. 295 or 292 or 294 or 293
297. heterotopic ossification.mp. or exp Ossification, Heterotopic/
298. myositis ossificans.mp. or exp Myositis Ossificans/
299. calcinosis.mp. or exp Calcinosis/
300. extraosseous calcification.mp.
301. metaplastic calcification.mp.
302. myo-osteosis.mp.
303. neurogenic osteoma.mp.
304. osseous heteroplasia.mp.
305. ossifying fibromyopathy.mp.
306. para-articular calcification.mp.
307. heterotopic calcification.mp.
308. pathological bone.mp.
309. pathological calcification.mp.
310. periarticular calcification.mp.
311. synostosis.mp.
312. ectopic bone.mp.
313. heterotopic bone.mp.
314. dystrophic ossification.mp.
315. ectopic ossification.mp.
316. metaplastic ossification.mp.
317. para-articular ossification.mp.
318. periarticular ossification.mp.
319. pathological ossification.mp.
320. ectopic calcification.mp.
321. soft tissue calcification.mp.
322. (vascular adj3 calcification).mp.
323. (aort$ adj3 calcification).mp.
324. (valv$ adj3 calcification).mp.
325. or/297–324
326. limit 325 to animal
327. limit 325 to human
328. 326 not 327
329. 325 not 328
330. limit 329 to english language
331. exp kidney disease/
332. exp kidney/
333. kidney.mp.
334. renal.af.
335. nephro$.af.
336. exp renal replacement therapy/
337. exp kidney, artificial/
338. (hemodialy$ or haemodialy$ or dialy$).af.
339. exp Kidney Glomerulus/
340. exp Kidney Function Tests/
341. ur?emia.tw.
342. exp Kidney Calculi/
343. (kidney stone$ or renal stone$ or renal calcul$ or kidney calcul$ or nephrolith$).af.
344. 343 not 342
345. exp nephrolithiasis/
346. or/331–345
347. allerg$.mp. or exp Hypersensitivity/

## b Overall Search Strategy for Outcomes of Upper Limits

Database: Ovid MEDLINE(R), CCTR (from 1966 to December 2008)

1. exp Vitamin D/
2. (25-hydroxy vit D or plasma vit D or 25OHD or 25-OHD).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
3. (25OHD3 or “25(OH)D3” or 25-OHD3 or “25-(OH)D3”).tw.
4. (“25(OH)D” or “25-(OH)D” or “25-OH-D”).tw.
5. 25-hydroxycholecalciferol.tw.
6. 25-hydroxyergocalciferol.tw.
7. calcidiol.tw.
8. Calcifediol/
9. (vit adj (d or d2 or d3)).mp.
10. Ergocalciferols/
11. Ergocalciferol$.tw.
12. Cholecalciferol/
13. Cholecalciferol$.tw.
14. calciferol.tw.
15. exp Calcium Carbonate/or exp Calcium Citrate/or exp Calcium Phosphates/or exp Calcium Malate/
16. or/1–15
17. supplement$.tw.
18. exp Dietary Supplements/to, ae, po, ut [Toxicity, Adverse Effects, Poisoning, Utilization]
19. No-Observed-Adverse-Effect Level/
20. upper limit$.tw.
21. UL.tw.
22. (excess$ or toxic$).tw.
23. vit d intox$.tw.
24. (noael or noel).tw.
25. (no observed adj2 effect$).tw.
26. or/17–25
27. 26 and 16
28. (ANIMALS not HUMAN).sh.
29. *Dialysis/or *hemodialysis/or *peritoneal dialysis/
30. 27 not 28
31. 30 not 29
32. limit 31 to (addresses or bibliography or biography or comment or dictionary or directory or duplicate publication or editorial or in vitro or interview or lectures or letter or news or “review”)
33. 31 not 32
34. limit 33 to english language
35. exp kidney disease/
36. exp kidney, artificial/
37. exp Kidney Function Tests/
38. ur?emia.tw.
39. (kidney stone$ or renal stone$ or renal calcul$ or kidney calcul$ or nephrolith$).af.
40. exp nephrolithiasis/
41. heterotopic ossification.mp. or exp Ossification, Heterotopic/
42. myositis ossificans.mp. or exp Myositis Ossificans/
43. calcinosis.mp. or exp Calcinosis/
44. extraosseous calcification.mp.
45. metaplastic calcification.mp.
46. myo-osteosis.mp.
47. neurogenic osteoma.mp.
48. osseous heteroplasia.mp.
49. ossifying fibromyopathy.mp.
50. para-articular calcification.mp.
51. heterotopic calcification.mp.
52. pathological bone.mp.
53. pathological calcification.mp.
54. periarticular calcification.mp.
55. synostosis.mp.
56. ectopic bone.mp.
57. heterotopic bone.mp.
58. dystrophic ossification.mp.
59. ectopic ossification.mp.
60. metaplastic ossification.mp.
61. para-articular ossification.mp.
62. periarticular ossification.mp.
63. pathological ossification.mp.
64. ectopic calcification.mp.
65. soft tissue calcification.mp.
66. (vascular adj3 calcification).mp.
67. (aort$ adj3 calcification).mp.
68. (valv$ adj3 calcification).mp.
69. or/41–68
70. Calcification, Physiologic/de [Drug Effects]
71. Hypercalcemia/
72. Kidney Calculi/
73. Nephrocalcinosis/
74. Urinary Calculi/
75. Bladder Calculi/
76. Ureteral Calculi/
77. Calcinosis/
78. Hypercalcemi$.tw.
79. (Burnett$ adj2 syndrome$).tw.
80. Hypercalciuri$.tw.
81. or/70–80
82. psoriasis.mp. or exp Psoriasis/
83. 81 or 69 or 82
84. 34 and 83
85. limit 84 to case reports
86. 84 not 85