# Appendixes

Appendix A Search strategy for primary studies

Appendix B Search strategy for systematic reviews

Appendix C Evidence Tables: A-E

Appendix C Evidence Tables: F-K

Appendix C Evidence Tables: L-Q

Appendix C Evidence Tables: R-Z

Appendix D Evaluation of existing systematic reviews and evidence tables of the qualified systematic reviews

Appendix E Blank Data Extraction Form and Quality Assessment Checklists

Appendix F Excluded Studies