# Acknowledgments

We would like to acknowledge with appreciation the following members of the Technical Expert Panel for their advice and consultation to the Tufts Evidence-based Practice Center during the preparation for this report:

- Steven Abrams, M.D.
- Professor of Pediatrics
- Baylor College of Medicine
- Section of Neonatology
- Texas Children’s Hospital
- Houston, Texas

- Stephanie Atkinson, Ph.D.
- Professor and Associate Chair
- Department of Pediatrics
- Biochemistry and Biomedical Sciences
- Health Sciences
- McMaster University
- Hamilton, Canada

- Patsy M. Brannon, Ph.D.
- Professor
- Division of Nutritional Sciences
- Cornell University
- Ithaca, New York

- Rebecca D. Jackson, M.D.
- Associate Professor
- Department of Internal Medicine
- Division of Endocrinology, Diabetes, and Metabolism
- The Ohio State University
- Columbus, Ohio

- Glenville Jones, Ph.D.
- Professor and Head
- Department of Biochemistry
- Queen’s University
- Ontario, Canada

- Susan Taylor Mayne, Ph.D., F.A.C.E.
- Professor
- Division of Chronic Disease Epidemiology
- Yale School of Public Health
- New Haven, Connecticut

- Clifford J. Rosen, M.D.
- Senior Scientist
- Maine Medical Center Research Institute
- Scarborough, Maine