# References

1 Smith C, Cowan C, Sensenig A, et al. Health spending growth slows in 2003. Health Aff (Millwood). Jan-Feb. 2005;24(1):185-94. [pmid: 15644387].
2 Moses H 3rd, Dorsey ER, Matheson DH, et al. Financial anatomy of biomedical research. JAMA. Sep 21. 2005;294(11):1333-42. [pmid: 16174691].
3 Cutler DM, Rosen AB, Vijan S. The value of medical spending in the United States, 1960–2000. N Engl J Med. Aug 31. 2006;355(9):920-7. [pmid: 16943404].
4 Arias E. United States life tables, 2004. National vital statistics reports. Hyattsville, MD. National Center for Health Statistics. 2007.
5 Agency for Healthcare Research and Quality. National Healthcare Disparities Report, 2003. Full Report. Rockville, MD. http://www.ahrq.gov/qual/nhdr03/fullreport/. 2003.
6 Agency for Healthcare Research and Quality. National Healthcare Disparities Report, 2004. Full Report. Rockville, MD. http://www.ahrq.gov/qual/nhdr04/fullreport/. 2004.
7 Agency for Healthcare Research and Quality. National Healthcare Disparities Report, 2005. Full Report. Rockville, MD. http://www.ahrq.gov/qual/nhdr05/fullreport/. 2005.
8 Agency for Healthcare Research and Quality. National Healthcare Disparities Report. 2006. Rockville, MD. http://www.ahrq.gov/qual/nhdr06/nhdr06.htm. 2006.
9 Agency for Healthcare Research and Quality. 2007. National Healthcare Disparities Report. Rockville, MD. U.S. Department of Health and Human Services, Agency for Healthcare Research and Quality. February. 2008. AHRQ Pub. No. 08-0041 2008.
10 Smedley BD, Stith AY, Nelson AR, editors. Unequal treatment: confronting racial and ethnic disparities in health care. Washington (DC). Institute of Medicine: National Academies Press. 2003.
11 Children’s Defense Fund. Improving children's health: Understanding children’s health disparities and promising approaches to address them. Available at http://www.childrensdefense.org/child-research-data-publications/data/Childrens-Health-Disparities-Report-2006.pdf. 2006.
12 Carter-Pokras O, Bacquet C. What is a "health disparity"?. Pub Health Rep. 2002;117(5):426-34. [pmid: 12500958].
13 Health Resources and Services Administration (HRSA). Community Health Worker National Workforce Study. ftp://ftp.hrsa.gov/bhpr/workforce/chw307.pdf. 2007.
14 Eng E, Parker E, Harlan C. Lay health advisor intervention strategies: a continuum from natural helping to paraprofessional helping. Health Educ Behav. Aug. 1997;24(4):413-7. [pmid: 9247821].
15 Dignan MB, Burhansstipanov L, Hariton J, et al. A comparison of two Native American Navigator formats: face-to-face and telephone. Cancer Control. Nov. 2005;12(Suppl 2):28-33. [pmid: 16327748].
16 Auslander W, Haire-Joshu D, Houston C, et al. A controlled evaluation of staging dietary patterns to reduce the risk of diabetes in African-American women. Diabetes Care. May. 2002;25(5):809-14. [pmid: 11978673].
17 Paskett E, Tatum C, Rushing J, et al. Randomized trial of an intervention to improve mammography utilization among a triracial rural population of women. J Natl Cancer Inst. Sep 6. 2006;98(17):1226-37. [pmid: 16954475].
18 Katz ML, Tatum CM, Degraffinreid CR, et al. Do cervical cancer screening rates increase in association with an intervention designed to increase mammography usage?. J Womens Health (Larchmt). Jan-Feb. 2007;16(1):24-35. [pmid: 17324094].
19 Derose KP, Fox SA, Reigadas E, et al. Church-based telephone mammography counseling with peer counselors. J Health Commun. Apr-Jun. 2000;5(2):175-88. [pmid: 11010348].
20 Duan N, Fox SA, Derose KP, et al. Maintaining mammography adherence through telephone counseling in a church-based trial. Am J Public Health. Sep. 2000;90(9):1468-71. [pmid: 10983211].
21 Derose KP, Hawes-Dawson J, Fox SA, et al. Dealing with diversity: recruiting churches and women for a randomized trial of mammography promotion. Health Educ Behav. Oct. 2000;27(5):632-48. [pmid: 11009131].
22 Stockdale SE, Keeler E, Duan N, et al. Costs and cost-effectiveness of a church-based intervention to promote mammography screening. Health Serv Res. Dec. 2000;35(5 Pt 1):1037-57. [pmid: 11130802].
23 Morisky DE, Lees NB, Sharif BA, et al. Reducing disparities in hypertension control: a community-based hypertension control project (CHIP) for an ethnically diverse population. Health Promotion Practice. 2002 04;3(2):264-75.
24 Prochaska JO, Velicer WF. The transtheoretical model of health behavior change. Am J Health Promot. 1997;12:38-48. [pmid: 10170434].
25 Bandura A. Social learning theory. Englewood Cliffs, NJ. Prentice Hall. 1977.
26 Becker MH. The health belief model and personal health behavior. Health Educ Monog. 1974;2(4).
27 Lujan J, Ostwald SK, Ortiz M. Promotora diabetes intervention for Mexican Americans. Diabetes Educ. Jul-Aug. 2007;33(4):660-70. [pmid: 17684167].
28 Perez LM, Martinez J. Community health workers: Social justice and policy advocates for community health and well-being. Am J Pub Health. 2008;98:11-4. [pmid: 18048789].
29 Eng E, Parker EA. Natural helper models to enhance a community's health and competence. DeCliemente R, Crosby R, Kegler M, editors. Emerging theories and models in health promotion research and practice. San Francisco. Jossey-Bass. 2002.
30 Minkler M, Wallerstein N. Improving health through community organization and community building: a health education perspective. Minkler M, editor. Community organizing and community building for health. 2nd ed. San Francisco. Jossey-Bass. 2004:26-50.
31 Gostin LO, Powers M. What does social justice require for the public’s health? Public health ethics and policy imperatives. Health Affairs. 2006;25(4):1053-60. [doi: 10.377/hlthaff.25.4]. [pmid: 16835186].
32 Fawcett SB, Paine-Andrews A, Francisco VT, et al. Using empowerment theory in collaborative partnerships for community health and development. Am J Community Psychol. Oct. 1995;23(5):677-97. [pmid: 8851345].
33 Freire P. Education for critical consciousness. New York. Continuum International Publishing Group. 2005.
34 Minkler M, Cox K. Creating critical consciousness in health: applications of Freire's philosophy and methods to the health care setting. Int J Health Serv. 1980;10(2):311-22. [pmid: 7372386].
35 Kenyon VA. Felshers and health promotion in the USSR. Physician Assist. 1985;9(7):25-6. 9. [pmid: 10314615].
36 UNICEF/WHO Management of sick children by community health workers. Accessed at http://www.unicef.org/publications/files/Management_of_Sick_Children_by_Community_Health _Workers.pdf. 2009 Feb 03. 2006.
37 World Health Organization. World Health Statistics Printed in France. 2007.
38 The Robert Graham Center. Access denied: a look at America's disenfranchised. 2007. [cited 2-13-09]; Available from: http://www.graham-center.org/online/etc/medialib/graham/documents/publications/mongraphs-books/2007/rgcmo-access-denied.Par.0001.File.tmp/rgcmo-access-denied.pdf.
39 Wilkinson DY. Indigenous community health workers in the 1960s and beyond. Braithwaite RL, Taylor SE, editors. Health issues in the black community. San Francisco, CA. Jossey-Bass, Inc. 1992:255-66.
40 Cauffman JG, Wingert WA, Friedman DB, et al. Community health aides: how effective are they?. Am J Public Health Nations Health. Oct. 1970;60(10):1904-9. [pmid: 5528482].
41 Kahssay HM, Taylor ME, Berman PA. Community health workers: the way forward. Geneva (CH). World Health Organization. 1998.
42 Minow M. Revisiting the issues: home visiting. The Future of Children. 1994;4(2):243-6. [pmid: 7804767].
43 Boston Public Health Commission. Community Health Education Center [Internet]. Boston (MA). Boston Public Health Commission. cited 2009 Feb 03. Available from http://www.bphc.org/programs/chec/. 2009.
44 Love MB, Legion V, Shim JK, et al. CHWs get credit: a 10-year history of the first college-credit certificate for community health workers in the United States. Health Promot Pract. 2004;5(4):418-28. [pmid: 15358914].
45 Witmer A, Seifer SD, Finocchio L, et al. Community health workers: integral members of the health care work force. Am J Public Health. Aug. 1995;85(8 Pt 1):1055-8. [pmid: 7625495].
46 Texas Legislative Council House Bill 1864, enrolled version. Austin (TX). Texas Legislative Council. last accessed February 7, 2009. Available from: http://www.legis.state.tx.us/tlodocs/76R/billtext/html/HB01864F.htm. 1864.
47 Minnesota Session Laws 2007, Chapter 147 (HF 1078-3E). Minnesota. 2007.
48 Brownstein JN, Bone LR, Dennison CR, et al. Community health workers as interventionists in the prevention and control of heart disease and stroke. Am J Prev Med. Dec. 2005;29(5 Suppl 1):128-33. [pmid: 16389138].
49 Norris SL, Chowdhury FM, Van Le K, et al. Effectiveness of community health workers in the care of persons with diabetes. Diabet Med. 2006;23(5):544-56. [pmid: 16681564].
50 Andrews JO, Felton G, Wewers ME, et al. Use of community health workers in research with ethnic minority women. J Nurs Scholarsh. 2004;36(4):358-65. [pmid: 15636417].
51 Rhodes SD, Foley KL, Zometa CS, et al. Lay health advisor interventions among Hispanics/Latinos: a qualitative systematic review. Am J Prev Med. Nov. 2007;33(5):418-27. [pmid: 17950408].
52 Lewin SA, Dick J, Pond P, et al. Lay health workers in primary and community health care. Cochrane Database Syst Rev. 2005(1):CD004015.
53 Gibbons MC, Tyus NC. Systematic review of US-based randomized controlled trials using community health workers. Johns Hopkins University Press. 2007.
54 Berkman N, Viswanathan M. Model Form for the Evaluation of Observational Studies Included in Systematic Literature Reviews. Durham, NC. RTI International. 2007.
55 Deeks JJ, Dinnes J, D'Amico R, et al. Evaluating non-randomised intervention studies. Health Technol Assess. 2003;7:iii-x. [PMID: 14499048].
56 Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health. 1998;52:377-84. [pmid: 9764259].
57 Owens DK, Lohr KN, Atkins D, et al. Grading the strength of a body of evidence when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. In press.
58 Agency for Healthcare Research and Quality. Methods Guide for Comparative Effectiveness Reviews, Version 1.0 [Draft posted Oct. 2007]. Rockville, MD. Available at: http://effectivehealthcare.ahrq.gov/repFiles/2007_10DraftMethodsGuide.pdf. 2007.
59 Sauaia A, Min SJ, Lack D, et al. Church-based breast cancer screening education: impact of two approaches on Latinas enrolled in public and private health insurance plans. Prev Chronic Dis. Oct. 2007;4(4):A99. [pmid: 17875274].
60 Welsh AL, Sauaia A, Jacobellis J, et al. The effect of two church-based interventions on breast cancer screening rates among Medicaid-insured Latinas. Prev Chronic Dis. Oct. 2005;2(4):A07. [pmid: 16164811].
61 Sung JF, Blumenthal DS, Coates RJ, et al. Effect of a cancer screening intervention conducted by lay health workers among inner-city women. Am J Prev Med. Jan-Feb. 1997;13(1):51-7. [pmid: 9037342].
62 Sung JF, Coates RJ, Williams JE, et al. Cancer screening intervention among black women in inner-city Atlanta--design of a study. Public Health Rep. Jul-Aug. 1992;107(4):381-8. [pmid: 1641433].
63 Taylor VM, Hislop TG, Jackson JC, et al. A randomized controlled trial of interventions to promote cervical cancer screening among Chinese women in North America. J Natl Cancer Inst. May 1. 2002;94(9):670-7. [pmid: 11983755].
64 Elder JP, Ayala GX, Campbell NR, et al. Interpersonal and print nutrition communication for a Spanish-dominant Latino population: Secretos de la Buena Vida. Health Psychol. Jan. 2005;24(1):49-57. [pmid: 15631562].
65 Elder JP, Ayala GX, Campbell NR, et al. Long-term effects of a communication intervention for Spanish-dominant Latinas. Am J Prev Med. Aug. 2006;31(2):159-66. [pmid: 16829333].
66 Hunter JB, de Zapien JG, Papenfuss M, et al. The impact of a promotora on increasing routine chronic disease prevention among women aged 40 and older at the U.S.-Mexico border. Health Educ Behav. Aug. 2004;31(4 Suppl):18S-28S. [pmid: 15296689].
67 Conway TL, Woodruff SI, Edwards CC, et al. Intervention to reduce environmental tobacco smoke exposure in Latino children: null effects on hair biomarkers and parent reports. Tob Control. Mar. 2004;13(1):90-2. [pmid: 14985605].
68 Barnes K, Friedman SM, Brickner Namerow P, et al. Impact of community volunteers on immunization rates of children younger than 2 years. Arch Pediatr Adolesc Med. May. 1999;153(5):518-24. [pmid: 10323634].
69 Rask KJ, LeBaron CW, Starnes DM. The costs of registry-based immunization interventions. Am J Prev Med. Nov. 2001;21(4):267-71. [pmid: 11701296].
70 LeBaron CW, Starnes DM, Rask KJ. The impact of reminder-recall interventions on low vaccination coverage in an inner-city population. Arch Pediatr Adolesc Med. Mar. 2004;158(3):255-61. [pmid: 14993085].
71 Barnes-Boyd C, Norr KF, Nacion KW. Promoting infant health through home visiting by a nurse-managed community worker team. Public Health Nursing. 2001 07;18(4):225-35. [pmid: 11468062].
72 Nacion KW, Norr KF, Burnett GM, et al. Validating the safety of nurse-health advocate services. Public Health Nurs. 2000 01;17(1):32-42. [pmid: 10675051].
73 Barth RP, Hacking S, Ash JR. Preventing child abuse: an experimental evaluation of the child parent enrichment project. J Primary Prevent. 1988;8(4):201-17.
74 Barth RP. An experimental evaluation of in-home child abuse prevention services. Child Abuse Negl. 1991;15(4):363-75. [pmid: 1959070].
75 Black MM, Dubowitz H, Hutcheson J, et al. A randomized clinical trial of home intervention for children with failure to thrive. Pediatrics. Jun. 1995;95(6):807-14. [pmid: 7539121].
76 Hutcheson JJ, Black MM, Talley M, et al. Risk status and home intervention among children with failure-to-thrive: follow-up at age 4. J Pediatr Psychol. Oct. 1997;22(5):651-68. [pmid: 9383928].
77 Caulfield LE, Gross SM, Bentley ME, et al. WIC-based interventions to promote breastfeeding among African-American women in Baltimore: effects on breastfeeding initiation and continuation. J Hum Lact. Mar. 1998;14(1):15-22. [pmid: 9543954].
78 Duggan AK, McFarlane EC, Windham AM, et al. Evaluation of Hawaii's Healthy Start Program. Future Child. Spring-Summer. 1999;9(1):66-90. discussion 177–8. [pmid: 10414011].
79 Graham AV, Frank SH, Zyzanski SJ, et al. A clinical trial to reduce the rate of low birth weight in an inner-city black population. Fam Med. Aug. 1992;24(6):439-46. [pmid: 1397814].
80 Olds DL, Robinson J, O'Brien R, et al. Home visiting by paraprofessionals and by nurses: a randomized, controlled trial. Pediatrics. Sep. 2002;110(3):486-96. [pmid: 12205249].
81 Korfmacher J, O'Brien R, Hiatt S, et al. Differences in program implementation between nurses and paraprofessionals providing home visits during pregnancy and infancy: a randomized trial. Am J Public Health. Dec. 1999;89(12):1847-51. [pmid: 10589314].
82 Olds DL, Robinson J, Pettitt L, et al. Effects of home visits by paraprofessionals and by nurses: age 4 follow-up results of a randomized trial. Pediatrics. Dec. 2004;114(6):1560-8. [pmid: 15574615].
83 St James PS, Shapiro E, Waisbren SE. The Resource Mothers Program for Maternal Phenylketonuria. Am J Public Health. May. 1999;89(5):762-4. [pmid: 10224992].
84 Schuler ME, Nair P, Black MM, et al. Mother-infant interaction: effects of a home intervention and ongoing maternal drug use. J Clin Child Psychol. Sep. 2000;29(3):424-31. [pmid: 10969426].
85 Silver EJ, Ireys HT, Bauman LJ, et al. Psychological outcomes of a support intervention in mothers of children with ongoing health conditions: the parent-to-parent network. J Commun Psychol. 1997;25(3):249-64.
86 Tessaro I, Campbell M, O'Meara C, et al. State health department and university evaluation of North Carolina's Maternal Outreach Worker Program. Am J Prev Med. Nov-Dec. 1997;13(6 Suppl):38-44. [pmid: 9455592].
87 Navaie-Waliser M, Martin SL, Tessaro I, et al. Social support and psychological functioning among high-risk mothers: the impact of the Baby Love Maternal Outreach Worker Program. Public Health Nurs. Jul-Aug. 2000;17(4):280-91. [pmid: 10943776].
88 Batts ML, Gary TL, Huss K, et al. Patient priorities and needs for diabetes care among urban African American adults. Diabetes Educ. May-Jun. 2001;27(3):405-12. [pmid: 11912801].
89 Gary TL, Bone LR, Hill MN, et al. Randomized controlled trial of the effects of nurse case manager and community health worker interventions on risk factors for diabetes-related complications in urban African Americans. Prev Med. Jul. 2003;37(1):23-32. [pmid: 12799126].
90 Gary TL, Hill-Briggs F, Batts-Turner M, et al. Translational research principles of an effectiveness trial for diabetes care in an urban African American population. Diabetes Educator. 2005(6):880-9.
91 Gary TL, Crum RM, Cooper-Patrick L, et al. Depressive symptoms and metabolic control in African-Americans with type 2 diabetes. Diabetes Care. Jan. 2000;23(1):23-9. [pmid: 10857963].
92 Vetter MJ, Bristow L, Ahrens J. A model for home care clinician and home health aide collaboration: diabetes care by nurse case managers and community health workers. Home Healthc Nurse. Sep. 2004;22(9):645-8. [pmid: 15359179].
93 Beckham S, Bradley S, Washburn A, et al. Diabetes management: utilizing community health workers in a Hawaiian/Samoan population. J Health Care Poor Underserved. May. 2008;19(2):416-27. [pmid: 18469413].
94 Frate DA, Johnson SA, Sharpe TR. Solutions to the problems of chronic disease management in rural settings. J Rural Health. Jan. 1985;1(1):52-9. [pmid: 10311750].
95 Frate DA, Whitehead T, Johnson SA. Selection, training, and utilization of health counselors in the management of high blood pressure. Urban Health. May. 1983;12(5):52-4. [pmid: 10262031].
96 Krieger JW, Takaro TK, Song L, et al. The Seattle-King County Healthy Homes Project: a randomized, controlled trial of a community health worker intervention to decrease exposure to indoor asthma triggers. Am J Public Health. Apr. 2005;95(4):652-9. [pmid: 15798126].
97 Krieger JK, Takaro TK, Allen C, et al. The Seattle-King County Healthy Homes Project: implementation of a comprehensive approach to improving indoor environmental quality for low-income children with asthma. Environ Health Perspect. Apr. 2002;110(Suppl 2):311-22. [pmid: 11929743].
98 Levine DM, Bone LR, Hill MN, et al. The effectiveness of a community/academic health center partnership in decreasing the level of blood pressure in an urban African-American population. Ethn Dis. Summer. 2003;13(3):354-61. [pmid: 12894960].
99 Ward HJ, Morisky DE, Lees NB, et al. A clinic and community-based approach to hypertension control for an underserved minority population: design and methods. Am J Hypertens. Feb. 2000;13(2):177-83. [pmid: 10701818].
100 Parker EA, Israel BA, Robins TG, et al. Evaluation of Community Action Against Asthma: a community health worker intervention to improve children's asthma-related health by reducing household environmental triggers for asthma. Health Educ Behav. Jun. 2008;35(3):376-95. [pmid: 17761540].
101 Gielen AC, McDonald EM, Wilson ME, et al. Effects of improved access to safety counseling, products, and home visits on parents' safety practices: results of a randomized trial. Arch Pediatr Adolesc Med. Jan. 2002;156(1):33-40. [pmid: 11772188].
102 Schwarz DF, Grisso JA, Miles C, et al. An injury prevention program in an urban African-American community. Am J Public Health. May. 1993;83(5):675-80. [pmid: 8484447].
103 Andersen MR, Yasui Y, Meischke H, et al. The effectiveness of mammography promotion by volunteers in rural communities. Am J Prev Med. Apr. 2000;18(3):199-207. [pmid: 10722985].
104 Fox SA, Pitkin K, Paul C, et al. Breast cancer screening adherence: does church attendance matter?. Health Educ Behav. Dec. 1998;25(6):742-58. [pmid: 9813745].
105 Krieger J, Collier C, Song L, et al. Linking community-based blood pressure measurement to clinical care: a randomized controlled trial of outreach and tracking by community health workers. Am J Public Health. Jun. 1999;89(6):856-61. [pmid: 10358675].
106 Jandorf L, Gutierrez Y, Lopez J, et al. Use of a patient navigator to increase colorectal cancer screening in an urban neighborhood health clinic. J Urban Health. Jun. 2005;82(2):216-24. [pmid: 15888638].
107 Campbell MK, James A, Hudson MA, et al. Improving multiple behaviors for colorectal cancer prevention among African American church members. Health Psychol. Sep. 2004;23(5):492-502. [pmid: 15367069].
108 Erwin DO, Spatz TS, Stotts RC, et al. Increasing mammography practice by African American women. Cancer Pract. Mar-Apr. 1999;7(2):78-85. [pmid: 10352065].
109 Mock J, McPhee SJ, Nguyen T, et al. Effective lay health worker outreach and media-based education for promoting cervical cancer screening among Vietnamese American women. Am J Public Health. Sep. 2007;97(9):1693-700. [pmid: 17329652].
110 Navarro AM, Senn KL, Kaplan RM, et al. Por La Vida intervention model for cancer prevention in Latinas. J Natl Cancer Inst Monogr. 1995(18):137-45.
111 Navarro AM, Senn KL, McNicholas LJ, et al. Por La Vida model intervention enhances use of cancer screening tests among Latinas. Am J Prev Med. Jul. 1998;15(1):32-41. [pmid: 9651636].
112 Navarro AM, McNicholas LJ, Senn KL, et al. Use of cancer screening tests among Latinas one and two years after participation in the Por La Vida Damos Cuenta program. J Women's Cancer. 2000;2(1):23-30.
113 Earp JA, Eng E, O'Malley MS, et al. Increasing use of mammography among older, rural African American women: results from a community trial. Am J Public Health. Apr. 2002;92(4):646-54. [pmid: 11919066].
114 Von Korff M, Moore JE, Lorig K, et al. A randomized trial of a lay person-led self-management group intervention for back pain patients in primary care. Spine. Dec 1. 1998;23(23):2608-15. [pmid: 9854760].
115 Smith MA, Garbharran H, Edwards MJ, et al. Health promotion and disease prevention through sanitation education in South African Zulu and Xhosa women. J Transcult Nurs. Jan. 2004;15(1):62-8. [pmid: 14768417].
116 Wilson TE, Fraser-White M, Feldman J, et al. Hair salon stylists as breast cancer prevention lay health advisors for African American and Afro-Caribbean women. J Health Care Poor Underserved. Feb. 2008;19(1):216-26. [pmid: 18263997].
117 Wendell DA, Cohen DA, LeSage D, et al. Street outreach for HIV prevention: effectiveness of a state-wide programme. Int J STD AIDS. May. 2003;14(5):334-40. [pmid: 12803941].
118 Becker DM, Yanek LR, Johnson WR Jr, et al. Impact of a community-based multiple risk factor intervention on cardiovascular risk in black families with a history of premature coronary disease. Circulation. Mar 15. 2005;111(10):1298-304. [pmid: 15769772].
119 Cene CW, Yanek LR, Moy TF, et al. Sustainability of a multiple risk factor intervention on cardiovascular disease in high-risk African American families. Ethn Dis. Spring. 2008;18(2):169-75. [pmid: 18507269].
120 Morse GA, Calsyn RJ, Klinkenberg WD, et al. An experimental comparison of three types of case management for homeless mentally ill persons. Psychiatr Serv. Apr. 1997;48(4):497-503. [pmid: 9090733].
121 Wolff N, Helminiak TW, Morse GA, et al. Cost-effectiveness evaluation of three approaches to case management for homeless mentally ill clients. Am J Psychiatry. Mar. 1997;154(3):341-8. [pmid: 9054781].
122 Pilote L, Tulsky JP, Zolopa AR, et al. Tuberculosis prophylaxis in the homeless. A trial to improve adherence to referral. Arch Intern Med. Jan 22. 1996;156(2):161-5. [pmid: 8546549].
123 Bone LR, Mamon J, Levine DM, et al. Emergency department detection and follow-up of high blood pressure: use and effectiveness of community health workers. Am J Emerg Med. Jan. 1989;7(1):16-20. [pmid: 2914043].
124 Corkery E, Palmer C, Foley ME, et al. Effect of a bicultural community health worker on completion of diabetes education in a Hispanic population. Diabetes Care. Mar. 1997;20(3):254-7. [pmid: 9051367].
125 Hiatt RA, Pasick RJ, Stewart S, et al. Cancer screening for underserved women: the Breast and Cervical Cancer Intervention Study. Cancer Epidemiol Biomarkers Prev. Aug. 2008;17(8):1945-9. [pmid: 18708383].
126 Forst L, Lacey S, Chen HY, et al. Effectiveness of community health workers for promoting use of safety eyewear by Latino farm workers. Am J Ind Med. Dec. 2004;46(6):607-13. [pmid: 15551366].
127 Williams JH, Belle GA, Houston C, et al. Process evaluation methods of a peer-delivered health promotion program for African American women. Health Promot Pract. April. 1. 2001. 2001;2(2):135-42.
128 Duggan A, Windham A, McFarlane E, et al. Hawaii's Healthy Start Program of home visiting for at-risk families: evaluation of family identification, family engagement, and service delivery. Pediatrics. Jan. 2000;105(1 Pt 3):250-9. [pmid: 10617732].
129 Chen LH, Gielen AC, McDonald EM. Validity of self reported home safety practices. Inj Prev. Mar. 2003;9(1):73-5. [pmid: 12642564].
130 Gold MR, Siegel JE, Russell LB, et al., editors. Cost-effectiveness in health and medicine. New York. Oxford University Press. 1996.
131 Haddix A, Teutsch SM, Corso PS, editors. Prevention effectiveness: a guide to decision analysis and economic evaluation. Oxford. Oxford University Press. 2003.
132 Ka'opua LS. Training community practitioners in a research intervention: practice examples at the intersection of cancer, Western science, and native Hawaiian healing. Cancer Control. Sep-Oct. 2003;10(5 Suppl):5-12. [pmid: 14581899].
133 Pichert JP. Evaluating teaching skills instruction for maternal-infant health care providers. J Nurs Staff Dev. Fall. 1985;1:105-9. [pmid: 3854326].
134 Robertson EM, Franklin AW, Flores A, et al. African American community breast health education: a pilot project. ABNF J. Jan-Feb. 2006;17(1):48-51. [pmid: 16596901].
135 Earp JA, Viadro CI, Vincus AA, et al. Lay health advisors: a strategy for getting the word out about breast cancer. Health Educ Behav. Aug. 1997;24(4):432-51. [pmid: 9247823].
136 Meister JS, Warrick LH, de Zapien JG, et al. Using lay health workers: case study of a community-based prenatal intervention. J Community Health. Feb. 1992;17(1):37-51. [pmid: 1564139].
137 Yu MY, Song L, Seetoo A, et al. Culturally competent training program: a key to training lay health advisors for promoting breast cancer screening. Health Educ Behav. Dec. 2007;34(6):928-41. [pmid: 17965228].
138 LaRowe TL, Wubben DP, Cronin KA, et al. Development of a culturally appropriate, home-based nutrition and physical activity curriculum for Wisconsin American Indian families. Prev Chronic Dis. Oct. 2007;4(4):A109. [pmid: 17875253].
139 Reinschmidt KM, Chong J. SONRISA: a curriculum toolbox for promotores to address mental health and diabetes. Prev Chronic Dis. Oct. 2007;4(4):A101. [pmid: 17875245].
140 Dick RW, Manson SM, Hansen AL, et al. The Native Telehealth Outreach and Technical Assistance Program: a community-based approach to the development of multimedia-focused health care information. Am Indian Alsk Native Ment Health Res. 2007;14(2):49-66. [pmid: 17874365].
141 Navarro AM, Raman R, McNicholas LJ, et al. Diffusion of cancer education information through a Latino community health advisor program. Prev Med. Aug-Sep. 2007;45(2–3):135-8. [pmid: 17604831].
142 Kelly PJ, Lesser J, Peralez-Dieckmann E, et al. Community-based violence awareness. Issues Ment Health Nurs. Mar. 2007;28(3):241-53. [pmid: 17454278].
143 Beck B, Young S, Ahmed S, et al. Development of a church-based cancer education curriculum using CBPR. J Health Care Poor Underserved. Feb. 2007;18(1):28-34. [pmid: 17337794].
144 Olney CA, Warner DG, Reyna G, et al. MedlinePlus and the challenge of low health literacy: findings from the Colonias project. J Med Libr Assoc. Jan. 2007;95(1):31-9. [pmid: 17252064].
145 Han HR, Kim KB, Kim MT. Evaluation of the training of Korean community health workers for chronic disease management. Health Educ Res. Aug. 2007;22(4):513-21. [pmid: 17032707].
146 Bergland JE, Heuer L, Lausch C. Diabetes lay educator case study: one woman's experience working with the Hispanic migrant and seasonal farmworkers. J Cult Divers. Fall. 2006;13(3):152-7. [pmid: 16989252].
147 Kuhajda MC, Cornell CE, Brownstein JN, et al. Training community health workers to reduce health disparities in Alabama's Black Belt: the Pine Apple Heart Disease and Stroke Project. Fam Community Health. Apr-Jun. 2006;29(2):89-102. [pmid: 16552287].
148 Perez M, Findley SE, Mejia M, et al. The impact of community health worker training and programs in NYC. J Health Care Poor Underserved. Feb. 2006;17(1 Suppl):26-43. [pmid: 16520505].
149 Balcazar H, Alvarado M, Hollen ML, et al. Salud Para Su Corazon-NCLR: a comprehensive promotora outreach program to promote heart-healthy behaviors among Hispanics. Health Promot Pract. Jan. 2006;7(1):68-77. [pmid: 16410422].
150 Martinez-Bristow Z, Sias JJ, Urquidi UJ, et al. Tobacco cessation services through community health workers for Spanish-speaking populations. Am J Public Health. Feb. 2006;96(2):211-3. [pmid: 16380561].
151 Kim S, Flaskerud JH, Koniak-Griffin D, et al. Using community-partnered participatory research to address health disparities in a Latino community. J Prof Nurs. Jul-Aug. 2005;21(4):199-209. [pmid: 16061166].
152 Smith A, Christopher S, McCormick AK. Development and implementation of a culturally sensitive cervical health survey: a community-based participatory approach. Women Health. 2004;40(2):67-86. [pmid: 15778139].
153 Hansen LK, Feigl P, Modiano MR, et al. An educational program to increase cervical and breast cancer screening in Hispanic women: a Southwest Oncology Group study. Cancer Nurs. Jan-Feb. 2005;28(1):47-53. [pmid: 15681982].
154 Morris LA, Ulmer C, Chimnani J. A role for Community HealthCorps members in youth HIV/AIDS prevention education. J Sch Health. Apr. 2003;73(4):138-42. [pmid: 12728611].
155 Bell RA, Hillers VN, Thomas TA. The Abuela Project: safe cheese workshops to reduce the incidence of Salmonella typhimurium from consumption of raw-milk fresh cheese. Am J Public Health. Sep. 1999;89(9):1421-4. [pmid: 10474564].
156 Meyers AR, Lett S, Grigg-Saito D, et al. Health care in the United States: a course for refugee health workers. Am J Public Health. Aug. 1989;79(8):1051-2. [pmid: 2751027].
157 Hatch JW. Outreach in Chatham County. N C Med J. Dec. 1987;48(12):633-5. [pmid: 3480435].
158 McElmurry BJ, Swider SM, Grimes MJ, et al. Health advocacy for young, low-income, inner-city women. Adv Nurs Sci. Jul. 1987;9(4):62-75.
159 Salber EJ. Where does primary care begin? The health facilitator as a central figure in primary care. Isr J Med Sci. Feb-Mar. 1981;17(2–3):100-11. [pmid: 7228635].
160 Bullock K, McGraw SA. A community capacity-enhancement approach to breast and cervical cancer screening among older women of color. Health Soc Work. Feb. 2006;31(1):16-25. [pmid: 16550844].
161 Teufel-Shone NI, Drummond R, Rawiel U. Developing and adapting a family-based diabetes program at the U.S.-Mexico border. Prev Chronic Dis. Jan. 2005;2(1):A20. [pmid: 15670473].
162 Littleton MA, Cornell CE, Dignan M, et al. Lessons learned from the Uniontown Community Health Project. Am J Health Behav. Jan-Feb. 2002;26(1):34-42. [pmid: 11795604].
163 Edgren KK, Parker EA, Israel BA, et al. Community involvement in the conduct of a health education intervention and research project: community action against asthma. Health Promot Pract. 2005 07;6(3):263-9. [pmid: 16020621].
164 Duthie P, Philippi E, Schultz J. Collaboration for training: a partnership to improve quality, consistency and cost-effectiveness of essential training for community health workers. Am J Health Educ. 2005 03;36(2):113-6.
165 Castaneda X, Clayson ZC, Rundall T, et al. Promising outreach practices: enrolling low-income children in health insurance programs in California. Health Promot Pract. 2003 10;4(4):430-8. [pmid: 14611028].
166 Ramos IN, May M, Ramos KS. Field action report. Environmental health training of promotoras in colonias along the Texas-Mexico border. Am J Public Health. 2001 04;91(4):568-70. [pmid: 11291367].
167 Maurana CA, Rodney MM. Strategies for developing a successful community health advocate program. Family Community Health. 2000 04;23(1):40-9.
168 Kash BA, May ML, Tai-Seale M. Community health worker training and certification programs in the United States: findings from a national survey. Health Policy. 2007;80(1):32-42. [pmid: 16569457].
169 Williams MP. Increasing participation in health promotion among older African-Americans. Am J Health Behav. 1996 11;20(6):389.
170 Valverde M, Felderman-Taylor J. HIV/AIDS outreach in southern New Mexico: from design to implementation. J HIV/AIDS Social Services. 2006 07;5(2):55-71.
171 White JA, Drechsel J, Johnson J. Faithfully fit forever: a holistic exercise and wellness program for faith communities. J Holist Nurs. 2006 06;24(2):127-31. [pmid: 16740903].
172 Hardy CM, Wynn TA, Huckaby F, et al. African American community health advisors trained as research partners: recruitment and training. Fam Comm Health. 2005 01;28(1):28-40.
173 Johnson RE, Green BL, Anderson-Lewis C, et al. Community health advisors as research partners: an evaluation of the training and activities. Fam Community Health. 2005 01;28(1):41-50. [pmid: 15625505].
174 Zuniga L, Ramos G, Williams DM. Promotora training as a preparation for entry into the work force. Tex J Rural Health. 2000;18(1):30-4.
175 Madigan ME, Smith-Wheelock L, Krein SL. Healthy hair starts with a healthy body: hair stylists as lay health advisors to prevent chronic kidney disease. Prev Chronic Dis. Jul. 2007;4(3):A64. [pmid: 17572968].
176 Navarro AM, McNicholas LJ, Cruz M, et al. Development and implementation of a curriculum on cancer screening for small groups of Latino women. J Cancer Educat. 2007;22(3):186-90.
177 Rauscher GH, Earp JA, O'Malley M. Relation between intervention exposures, changes in attitudes, and mammography use in the North Carolina Breast Cancer Screening Program. Cancer Epidemiol Biomarkers Prev. May. 2004;13(5):741-7. [pmid: 15159304].
178 von Elm E, Altman DG, Egger M, et al. The Strengthening the Reporting of Observational Studies in Epidemiology (STROBE) statement: guidelines for reporting observational studies. J Clin Epidemiol. Apr. 2008;61(4):344-9. [pmid: 18313558].
179 Altman DG, Schulz KF, Moher D, et al. The revised CONSORT statement for reporting randomized trials: explanation and elaboration. Ann Intern Med. Apr 17. 2001;134(8):663-94. [pmid: 11304107].
180 Glasgow RE. Translating research to practice: lessons learned, areas for improvement, and future directions. Diabetes Care. 2003;26:2451-6. [pmid: 12882877].
181 Woolf SH. The meaning of translational research and why it matters. JAMA. Jan 9. 2008;299(2):211-3. [pmid: 18182604].
182 Sung NS, Crowley WF Jr, Genel M, et al. Central challenges facing the national clinical research enterprise. JAMA. Mar 12. 2003;289(10):1278-87. [pmid: 12633190].
183 Glasgow RE, Emmons KM. How can we increase translation of research into practice? Types of evidence needed. Annu Rev Public Health. 2007;28:413-33. [pmid: 17150029].
184 Glasgow RE, Klesges LM, Dzewaltowski DA, et al. The future of health behavior change research: what is needed to improve translation of research into health promotion practice?. Ann Behav Med. Feb. 2004;27(1):3-12. [pmid: 14979858].
185 Tunis SR, Stryer DB, Clancy CM. Practical clinical trials: increasing the value of clinical research for decision making in clinical and health policy. JAMA. Sep 24. 2003;290(12):1624-32. [pmid: 14506122].
186 Glasgow RE, Vogt TM, Boles SM. Evaluating the public health impact of health promotion interventions: the RE-AIM framework. Am J Public Health. Sep. 1999;89(9):1322-7. [pmid: 10474547].
187 Whitlock EP, Lin JS, Liles E, et al. Screening for colorectal cancer: a targeted, updated systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. Nov 4. 2008;149(9):638-58. [pmid: 18838718].
188 Centers for Disease Control and Prevention (CDC). Use of colorectal cancer tests--United States, 2002, 2004, 2006. MMWR. 2008;57:253-8. [pmid: 18340331].
189 Schootman M, Jeffe DB, Baker EA, et al. Effect of area poverty rate on cancer screening across US communities. J Epidemiol Community Health. Mar. 2006;60(3):202-7. [pmid: 16476748].
190 Meissner HI, Breen N, Klabunde CN, et al. Patterns of colorectal cancer screening uptake among men and women in the United States. Cancer Epidemiol Biomarkers Prev. Feb. 2006;15(2):389-94. [pmid: 16492934].
191 Honeycutt AA, Clayton L, Khavjou O, et al. Guide to analyzing the cost-effectiveness of community public health prevention approaches. Prepared for the Assistant Secretary for Planning and Evaluation (ASPE). http://aspe.hhs.gov/health/reports/06/cphpa/report.pdf. 2006. March.