# Executive Summary

## Introduction

The United States has experienced remarkable improvements in public health and medical progress throughout much of the twentieth century, including major advances in pharmaceutical and medical device innovation and gains in life expectancy. These improvements, however, have not been accessible to all parts of U.S. society. Substantial disparities in life expectancy, health, and health care persist. Although many actors—including health care systems, insurers, health care providers, and patients—contribute to these disparities, bias, discrimination, and stereotyping during the clinical encounter also explain health care disparities. Experts recommend reducing fragmentation in health care systems, improving awareness on the part of health care providers of these problems, strengthening culturally competent approaches to the delivery of health care, and increasing the diversity of the health care workforce, as strategies to reduce health care disparities. A core component in recommendations to address healthcare disparities is the involvement of the community: specifically, the involvement of community health workers (CHWs).

The RTI International–University of North Carolina at Chapel Hill Evidence-based Practice Center (RTI-UNC EPC) conducted a systematic review on outcomes of CHW interventions. The review addressed four key questions (KQs):

- KQ 1. How do CHWs interact with participants? Specifically, what is the place of service, type of service, type of educational materials used, duration of interaction with participants, and length of followup?
- KQ 2. What is the impact of CHWs on outcomes, particularly knowledge, behavior, satisfaction, health outcomes, and health care utilization?
- KQ 3. What is known about the cost-effectiveness of CHWs for improving health outcomes?
- KQ 4a. What are characteristics of training for CHWs in the outpatient setting?
- KQ 4b. Are particular training characteristics associated with improved outcomes for patients?

## Methods

We searched MEDLINE®, Cochrane Collaboration resources, and the Cumulative Index to Nursing and Allied Health Literature for studies published in English from 1980 through November 2008 in the United States. We refined KQs in collaboration with a panel of technical experts. We searched data sources using more than 10 terms for CHWs, including the Medical Subject Heading term “community health aides.” We used standard Evidence-based Practice Center methods of dual review of abstracts, full-text articles, abstractions, quality ratings, and strength of evidence grades. We resolved disagreements by consensus. We identified 53 studies addressing KQ 1 and KQ 2, 6 studies addressing KQ 3, and 9 studies addressing KQ 4.

## Results

### KQ 1: Characteristics of Community Health Worker Interaction with Participants

KQ 1 asks for descriptions of the interaction between CHWs and participants; specifically, we examined place of service, type of service, type of educational materials used, duration of interaction with participants, and length of follow-up. CHWs interacted with participants in a broad array of locations, using a spectrum of materials at varying levels of intensity. Studies usually described the place of service and type of intervention in some detail. Across the studies, one-on-one interventions generally occurred in the home, over the telephone, or in a medical setting; by contrast, group interventions tended to take place in a community setting. Studies described types of educational materials poorly or not at all. Studies inconsistently reported duration of interaction with participants and length of followup (the number and length of sessions), and studies did not always clarify whether their reporting was based on protocol or on actual experience.

We synthesized the variety of ways in which CHWs can interact with participants into a single measure of intensity that serves as a proxy of resource allocation. We classified interactions that reported at least four of six elements suggesting a higher resource utilization (one-on-one, face-to-face, 1 hour per session or more, 3 or more months’ duration, three or more interactions, and tailored materials) as high intensity; interventions with two or three elements as moderate intensity; and interventions with only one or none of the elements as low intensity. Of the total of 53 studies, we classified 27 as high intensity, 18 as moderate intensity, and 8 as low intensity. The intensity of CHW interventions varied by clinical context: maternal and child health and chronic disease management interventions were all moderate or high intensity, whereas prevention and screening studies were more likely to include low-intensity interventions.

### KQ 2: Outcomes of Community Health Worker Interventions

KQ 2 asks about the impact of CHWs on outcomes, with specific attention to the following five domains: knowledge, behavior, satisfaction, health outcomes, and health care utilization. In addition, we summarize results by a key source of heterogeneity, the clinical context of the CHW intervention.

### Summary by Outcomes

Knowledge. The five studies reporting information on knowledge together provided moderate strength of evidence that CHW interventions improve the knowledge of participants on disease prevention and cancer screening, compared with other alternatives, and provided low strength of evidence that CHW interventions improve knowledge of label reading among diabetics, compared with usual care, but these studies gave insufficient evidence for knowledge of other issues related to the management of diabetes. This literature did not compare CHWs with a comprehensive range of usual care providers; we cannot therefore conclude that CHWs outperform all alternatives in improving participant knowledge. For the small subset of comparators and outcomes included in this literature, the studies together suggest that CHW interventions can improve participant knowledge when compared with alternative approaches such as no intervention, media, mail, or usual care plus pamphlets.

Behavior. Twenty-two studies reported on the effect of CHW interventions on participant behavior. The evidence for workplace safety, diabetes mellitus, and the use of bedding encasements for asthma, from five studies, suggested that CHW interventions result in improvements in participant behavior when compared with alternatives such as a community intervention, a lower-intensity CHW intervention, and usual care combined with a pamphlet. The strength of evidence is moderate for the use of bedding encasements for asthma and low for workplace safety and diabetes mellitus. The evidence for disease prevention, improving the environment for child well-being, planned use of cancer screening tests, and breast self-examination, from 14 studies, is mixed, with some studies demonstrating a statistically significant benefit of the CHW arm, and others demonstrating a lack of significant difference. The strength of evidence for these outcomes is low. The evidence for health promotion among Latinas, injury prevention at home, and smoking cessation to reduce asthma, from five studies, failed to demonstrate that CHW interventions resulted in significantly different outcomes than alternatives; the strength of evidence for these outcomes is low.

Together these studies suggest that CHW interventions can, in some instances, result in greater positive changes in participant behavior when compared with a range of alternatives (including no intervention, community intervention, usual care plus a newsletter, media, print, a less intense or delayed CHW arm, or a combination of interventions). In other instances, CHW interventions provided no statistically different benefit when compared with a range of alternatives. When the alternative requires greater resource allocation, as with the use of health care professionals, the absence of statistically significant differences may favor the use of CHWs.

Satisfaction. A single study, focusing on mental health among the homeless, found no differences between study arms in participant satisfaction; the strength of evidence for this outcome is low.

Health outcomes. The literature examined CHW effectiveness on a range of outcomes: 27 of 53 studies reported health outcomes. Moderate strength of evidence exists that CHW interventions improve health outcomes for two clinical areas (improving back pain and improving psychosocial outcomes among caregivers of children with asthma) when compared with either a lower-intensity CHW intervention or a delayed-intervention control group (three studies). The evidence for other outcomes (pediatric immunizations, prenatal care and perinatal outcomes, child development, environment conducive to child well-being, mental health, diabetes, and asthma symptoms), from 22 studies, is mixed, with some studies suggesting that CHW interventions are more effective than alternatives (including no intervention, usual care, and nurses), and other studies showing no difference between CHW interventions and alternatives. For disease prevention (specifically, reduction in body mass index), hypertension, and mental health, the evidence from five studies suggests no difference between CHW interventions and alternative approaches, including the use of CHWs in a lesser capacity, nurses, and print materials; the strength of evidence for these outcomes is low.

Together these studies showed that CHW interventions had a greater effect on some health outcomes when compared with alternatives such as no intervention, usual care, and nurses, but these findings were not consistent across all studies; several studies found no statistically significant benefit of the CHW arm when compared with alternative approaches.

Health care utilization. More than one-half of the identified studies reported on health care utilization. Fifteen studies provided moderate strength of evidence that CHW interventions increase appropriate health care utilization for disease prevention, mammography, infectious diseases, and asthma when compared with a range of alternatives such as no intervention, mail, print, or a less intense CHW arm. Two studies offered low strength of evidence that CHW interventions provide statistically significant benefits in health care utilization for two outcomes: prenatal and perinatal care (when compared with nurses) and hypertension (when compared with usual care). For Pap smears, six studies provided mixed evidence, with some studies suggesting a statistically significant benefit for the CHW arm, and other studies suggesting no significant differences; the strength of evidence for this outcome is low. For health promotion among Latinas, child well-being, clinical breast examination, colorectal cancer screening, and mental health, evidence from nine studies suggested no difference between the CHW intervention and alternatives; the strength of evidence for these outcomes is low.

Together these studies provided low to moderate evidence that CHW interventions increase appropriate health care utilization (e.g., more use of cancer screening tests, less use of emergency services) when compared with a range of alternatives for disease prevention (specifically, medical follow-up for elevated blood pressure), mammography, infectious diseases, and asthma; for other reported outcomes, the evidence was mixed or does not show a statistically significant benefit of the CHW arm.

### Summary Findings by Clinical Context

Health promotion and disease prevention. Eleven studies addressed health promotion and disease prevention, including pediatric immunizations, cardiovascular disease, diabetes prevention, HIV prevention, secondhand smoke exposure, colorectal cancer prevention, and general preventive care. Two studies on disease prevention found that CHW interventions versus print or no intervention were more effective in changing knowledge. Results for CHW interventions on behavior outcomes were mixed, with one-half of the studies favoring CHW intervention versus control groups, which consisted of no intervention, media, print, or a combination of interventions. None of the studies evaluated outcomes in the area of satisfaction. Results for CHW interventions on health outcomes, available from four studies, were also mixed.

The results suggest that CHW interventions may serve as an effective means of improving knowledge outcomes and possibly other outcomes related to preventing disease in underserved, minority populations.

Injury prevention. Three studies assessed injury prevention measures and associated behavioral outcomes: two focused on home injury prevention, and one considered workplace injury prevention. One study found improvements in behavior associated with CHW interventions when compared with a minimal community intervention, and one found mixed results with CHW interventions showing a statistically significant benefit in some measures but controls (with no intervention) showing a statistically significant benefit over CHW interventions for other measures. One study showed no significant difference in behavior between CHW interventions and health care professionals. The mixed results preclude any firm conclusions regarding the benefit of CHW interventions for injury prevention behaviors.

Maternal and child health. Fifteen studies meeting our inclusion criteria involved primarily maternal health, child health, or both and reported mainly on health outcomes. A statistically significant benefit of CHWs over standard care was shown most prominently in rapidity of metabolic control for mothers with phenylketonuria (PKU) and in the mental development of infants of mothers with PKU. CHW interventions were associated with a greater likelihood of initiating breastfeeding among African Americans, more frequent use of nonviolent discipline methods by parents, and higher parenting efficacy scores when compared with video-intervention or no-intervention controls. CHWs were also associated with significant attenuation in the decline of cognitive and motor development among infants with failure to thrive and with a lesser degree of increase in depressive symptoms among postpartum women when compared with no intervention. No significant advantage to CHW intervention was seen for improvements in incidence of low birth weight, presence of neonatal or infant health problems, language development, maternal stress or self-esteem, continuation of breastfeeding beyond 1 week, tobacco exposure for children of smokers, continued drug use among mothers with known prior drug use, growth of children with failure to thrive, or incidence of child maltreatment when compared with nurse interventions, multidisciplinary specialty clinical care, video or print intervention, routine health care, or no intervention.

Most studies involving CHWs for maternal and child health have been concerned with high-risk populations. For maternal and child health, CHWs appear to be most beneficial when addressing existing health conditions instead of potential conditions (i.e., primary prevention). Of the 15 studies that were evaluated, 8 studies reported statistically significant benefit to CHWs, compared with nurse interventions, multidisciplinary specialty clinical care, video or print intervention, routine health care, or no intervention. CHWs have not yet been shown to improve key health outcomes relating to maternal and child health such as prematurity, low birth weight, sustained breastfeeding, or child maltreatment relative to other alternatives such as video or print intervention, routine health care, or no intervention. The lack of such findings suggests that either further research is needed to demonstrate benefits or that there is a true lack of benefit for CHWs in this domain.

Cancer screening. Fifteen studies examining knowledge or health care utilization outcomes of CHW interventions for improving breast, cervical, or colorectal cancer screening met inclusion criteria for this systematic review. Together the 15 studies suggest limited evidence of improvement in knowledge in the CHW arm, compared with alternative approaches such as media or mail, and these studies also suggest conflicting findings on the effect of CHWs on planned or actual behavior changes—specifically, breast self-examination—when compared with no intervention, delayed intervention, mail, minimal CHW, or usual care. The volume of evidence on these outcomes is limited; the quality and design of the studies limit the interpretation of available evidence. Regarding health care utilization, our findings from limited evidence suggest that CHW interventions are not effective in comparison with other alternatives (such as no intervention, mail, tailored print and video, and minimal CHW) in raising the rates of clinical breast examination or colorectal cancer screening. More substantial evidence exists on Pap smears and mammography. The evidence suggests that the CHW arm is at least as effective as other alternatives (such as mail or lower-intensity CHW interventions) in improving Pap smear rates, but more effective than other alternatives (such as no intervention, media, print, community interventions, and usual care) only with low- and moderate-intensity interventions (rather than high-intensity interventions). Studies demonstrated significantly greater improvements in the CHW arm, compared with the alternative (no intervention, mail, print, or minimal CHW) in the main analysis or in subgroup analysis among low-income, minority, or other underserved subsamples.

CHW interventions were not demonstrated to be more effective than alternatives for increasing the utilization of breast self-examination, clinical breast examination, or colorectal cancer screening. CHWs can serve as a means of improving utilization of Pap smear tests and mammograms for underserved populations; the effectiveness of CHWs for other outcomes requires further research.

Chronic disease management. Thirteen studies addressed disease management, including diabetes mellitus, hypertension, asthma, back pain, mental health, and tuberculosis. Only one of the studies in the area of chronic disease management addressed knowledge outcomes. Two of four CHW interventions on diabetes and two asthma studies addressed behavior changes, comparing the CHW arm with usual care or a less intense CHW arm. These studies found that CHW interventions provided statistically significant benefit for diabetes and for use of bedding encasements in asthma, but not for smoking cessation. Only the mental health study addressed satisfaction outcomes, and this study did not demonstrate a difference between the CHW group and the control. Regarding health outcomes, two of four studies focusing on diabetes management found that a CHW intervention was more effective than usual care in decreasing hemoglobin A1c. None of the studies addressing hypertension management showed a significant difference in blood pressure control between groups. Two asthma studies demonstrated that CHW interventions were more effective than alternatives in reducing unscheduled health care services, improving psychological outcomes, and changing behavior, although symptom measures improved equally in each group. With the exception of asthma, the majority of CHW interventions for chronic disease management (specifically, diabetes, hypertension, and mental health) failed to show consistently greater improvement in health outcomes than usual care. By contrast, four of five studies on chronic disease management found that a CHW intervention was more effective than usual care or a less intense CHW arm in improving health care utilization.

### KQ 3: Cost-Effectiveness of Community Health Worker Interventions

We identified six studies in the literature providing economic analyses of CHW interventions. All of the studies included in our review estimated intervention program costs, but not all reported the specific components of those costs or the year for which costs were estimated. None of the CHW intervention evaluations that included an economic analysis reported a standard measure of costs per quality-adjusted life year saved, as recommended in recent guides for performing economic evaluations. One study did report on the costs per life-year saved of the CHW intervention, but potential biases in measurement limit the interpretation of results. We found insufficient evidence to evaluate whether CHW interventions are a cost-effective alternative to clinical interventions to promote health and prevent disease.

### KQ 4: Training of Community Health Workers

We found only nine studies meeting our inclusion criteria that described the training of CHWs. All included studies reported evidence of improvement in knowledge or skills, and many focused on aspects of training relevant to the specific health concern. Few reported on training for cultural competence, recruitment and retention process skills, intake and assessment, or protocol delivery. The failure to report on these elements presents a roadblock to identifying critical elements of a standardized curriculum applicable to all CHWs.

No studies reported on the effects of CHW training on health outcomes. The question of how to tailor CHW training to improve health outcomes is a significant gap for future studies to address.

## Discussion

CHW interventions have the potential to address two fundamental imperatives for improving health care in the United States: the need to address substantial and persistent health care disparities, and the need to translate more research into practice. CHWs, by virtue of their role as a bridge to the health care system, can help to disseminate widely efficacious interventions to populations that rarely benefit from health care advances.

Evidence about the effectiveness of CHWs relative to other choices is, however, mixed. Some studies demonstrated statistically significant benefits of the CHW approach, compared with other choices; other studies showed mixed results or no statistically significant differences between study arms. For the latter studies, one explanation is a lack of true benefit of the CHW arm relative to other choices. In addition, the choice of controls (including health professionals and CHWs in a lesser capacity), inadequate study power, and the Hawthorne effect may explain the lack of significant differences between CHWs and alternatives. The variation in and inadequate reporting on components of CHW interventions limit assessments of whether high-intensity interventions deliver greater value than low- or moderate-intensity interventions.

We found limited evidence that suggests that CHW interventions can improve participant knowledge when compared with alternative approaches such as no intervention, media, mail, or usual care plus pamphlets. We found mixed evidence for CHW effectiveness on participant behavior change and health outcomes: some studies suggested that CHW interventions can result in greater improvements in participant behavior and health outcomes when compared with various alternatives, but other studies suggested that CHW interventions provide no statistically different benefits. Low or moderate strength of evidence suggests that CHWs can increase appropriate health care utilization for some interventions. The literature showed mixed results of effectiveness when analyzed by clinical context: CHW interventions had the greatest effectiveness relative to alternatives for some disease prevention, asthma management, cervical cancer screening, and mammography screening outcomes. CHW interventions were not significantly different from alternatives for clinical breast examination, breast self-examination, colorectal cancer screening, chronic disease management, or most maternal and child health interventions. We found insufficient evidence to evaluate the cost-effectiveness of CHW interventions relative to other public health interventions.

Our review suggests that CHWs may serve as a means of improving outcomes for underserved populations for some health conditions, as described above. Other health concerns require further research that addresses the methodological limitations of prior studies to fully evaluate the effectiveness of CHW interventions.