# Discussion

This chapter discusses our findings for four key questions (KQs) relating to the interaction between community health workers (CHWs) and clients (KQ 1), outcomes of CHW interventions (KQ 2), costs of CHW interventions (KQ 3), and training of CHWs (KQ 4). As noted in earlier chapters, KQs 1 and 4 are largely descriptive. KQs 2 and 3 are more analytic; they focus on health and cost-effectiveness outcomes. We specify in this discussion the strength of the evidence for the KQs related to outcomes (KQ 2) and cost-effectiveness (KQ 3); we also evaluate the applicability of studies included for outcomes (KQ 2). We refer readers to Chapter 2 for methods for evaluating the strength of evidence and quality of studies.

The strength of evidence for each outcome incorporates grades for risk of bias, consistency, directness, precision, and the presence of other modifying factors. Our approach is based on one developed by the Evidence-based Practice Center program for its comparative effectiveness review activities.57 In the outcome-specific tables that follow, our overall grade of the strength of evidence appears in the far right column; grades for key domains are in the intermediate columns.

In this review, we ultimately had grades of only moderate or low. To recapitulate, moderate means that we have moderate confidence that the evidence reflects the true effect; further research may change our confidence in the estimate of effect and in fact may change the estimate. Low means that we have only low confidence that the evidence reflects the true effect; further research is likely to change the confidence in the estimate of effect and is likely to change the estimate.57

## Interactions between Community Health Workers and Clients (KQ 1)

KQ 1 asks for descriptions of the interaction between CHWs and participants; specifically, we examined place of service, type of service, type of educational materials used, duration of interaction with participants, and length of followup. We identified 53 studies with 79 citations in all, addressing KQ 1.^15–23,27,59–105,107–114,116–124,126–128^

CHWs interacted with participants in a broad array of locations, using a spectrum of materials at varying levels of intensity. Studies usually described the place of service and type of intervention in some detail. Across the studies, one-on-one interventions generally occurred in the home, on the telephone, or in a medical setting; by contrast, group interventions tended to take place in a community setting. Studies described types of educational materials poorly or not at all. Studies inconsistently reported duration of interaction with participants and length of followup (the number and length of sessions), and they did not always clarify whether their reporting was based on protocol or on actual experience. The frequent failure to distinguish between protocol and actual experience represents a missed opportunity to explore the balance between planned and actual resource allocation and to identify strategies to translate effective CHW interventions into a variety of community settings.

We synthesized the variety of ways that CHWs can interact with participants into a single measure of intensity that serves as a proxy of resource allocation. Interactions that reported at least four of six elements suggesting a higher intensity (one-on-one, face-to-face, 1 hour per session or more, 3 or more months’ duration, three or more interactions, and tailored materials) were classified as high intensity. Interventions with two or three elements were classified as moderate intensity. Interventions with only one or none of the elements of high intensity were classified as low intensity.

Of the total of 53 studies, we classified 27 as high intensity,16–18,27,61,62,64,65,67,68,71–98,100,120,121,127,128 18 as moderate intensity,15,23,63,66,69,70,99,101,102,105,106,109–112,114,116,118,119,122–125 and 8 as low intensity.19–22,59,60,103,104,107,108,113,117,126

The intensity of CHW interventions varied by clinical context (Table 35). Maternal and child health and chronic disease management interventions were all moderate or high intensity, whereas prevention and screening studies were more likely to involve low-intensity interventions.

Table 35 Number of studies, by clinical focus and intensity of interventions

Primary Clinical Context | Low Intensity (percentage) | Moderate Intensity (percentage) | High Intensity (percentage) | Total Number of Studies (percentage)
Health promotion and disease prevention | 2^107,117^ (18.2) | 4^66,69,70,105,118,119^ (36.4) | 5^16,64,65,67,68,71,127^ (45.5) | 11 (100)
Injury prevention | 1^126^ (33.3) | 2^101,102^ (66.7) | None | 3 (100)
Maternal and child health | None | None | 15^71–87^ (100) | 15 (100)
Cancer screening | 6^19–22,59,60,103,104,107,108,113^ (40.0) | 7^15,63,106,109–112,116,125^ (46.7) | 2^17,18,61,62^ (13.3) | 15 (100)
Chronic disease management | None | 5^23,99,114,122–124^ (38.5) | 8^27,88–98,100,120^ (61.5) | 13 (100)
Total (may be less than sum of rows because of overlapping studies) | 8 | 18 | 27 | 53

## Outcomes of Community Health Worker Interventions (KQ 2)

KQ 2 asks about the impact of CHWs on outcomes, with specific attention to the following five domains: knowledge, behavior and behavior change, satisfaction, health outcomes, and health care utilization. A key source of heterogeneity is the clinical context of the CHW intervention. The applicability of our findings is related to the clinical context of intervention. Studies targeted one or more of five primary contextual categories and a wide array of specific topic areas (number of subdomains in parentheses): health promotion and disease prevention (3), injury prevention (2), maternal and child health (3), cancer screening (6), and chronic disease management (6); collectively the focus of the studies in this review covered 20 distinct clinical or public health activities. Four studies overlapped primary clinical categories.67,68,71,107

As Table 36 demonstrates, we found numerous research gaps in the key clinical areas and domains. Satisfaction and knowledge are virtually ignored by studies in this evidence base. By contrast, health outcomes and health care utilization are better represented by studies we included; more than one-half of the studies included one or both of these outcomes.

Table 36 Summary of studies reporting on outcomes by primary clinical context and subtopic

Primary Clinical Context and Subdomain | Number of Studies by Outcomes
Primary Clinical Context and Subdomain | Knowledge | Behavior | Satisfaction | Health Outcomes | Health care utilization | Total^*^
Health promotion and disease prevention
Health promotion and disease prevention: pediatric immunizations | None | None | None | 3 | None | 3
Health promotion and disease prevention: health promotion – Latina health | None | 1 | None | None | 1 | 2
Health promotion and disease prevention: disease prevention | 2 | 5 | None | 1 | 1 | 6
Injury prevention
Injury prevention: home safety | None | 2 | None | None | None | 2
Injury prevention: workplace safety | None | 1 | None | None | None | 1
Maternal and child health
Maternal and child health: prenatal care and perinatal outcomes | None | None | None | 5 | 1 | 6
Maternal and child health: child development | None | None | None | 4 | None | 4
Maternal and child health: environment conducive to child well-being | None | 3 | None | 7 | None | 10
Cancer screening
Cancer screening (overall) | 2 | 2 | None | None | None | 2
Cancer screening: breast self-examination | None | 5 | None | None | None | 5
Cancer screening: Pap smears | None | None | None | None | 6 | 6
Cancer screening: mammography | None | None | None | None | 11 | 11
Cancer screening: clinical breast examination | None | None | None | None | 4 | 4
Cancer screening: colorectal cancer screening | None | None | None | None | 2 | 2
Chronic disease management
Chronic disease management: diabetes mellitus | 1 | 2 | None | 4 | None | 4
Chronic disease management: hypertension | None | None | None | 3 | 1 | 4
Chronic disease management: infectious diseases | None | None | None | None | 1 | 1
Chronic disease management: back pain | None | None | None | 1 | None | 1
Chronic disease management: mental health | None | None | 1 | 1 | 1 | 1
Chronic disease management: asthma | None | 2 | None | 2 | 2 | 2
Total^*^ | 5 | 22 | 1 | 27 | 30 | 53

* Total may be less than sum of cells because of overlapping studies.

In the section below, we discuss the strength of evidence for these five primary outcome domains and specific subdomains, reflecting the clinical context of the intervention. We follow the examination of outcomes with a summary of results for each clinical context and subdomain and then consider applicability.

We identified 53 studies comprising 79 citations addressing KQ 2. Thirty-eight were randomized controlled trials (RCTs)16–18,27,61,62,64,65,67,68,71–98,100,106,120,121,127,128 and 15 were observational studies.59,60,71,72,83,86,87,93–95,102,108,113,116,117,123,125,126 Of the 53 studies, we rated 4 as good quality,17,18,69,70,96,97,103 29 as fair,16,27,59–63,66–68,72,75,76,79–85,88–93,98,100,101,105,106,108,109,114,117,122,124,125,127 and 20 as poor.15,19–23,64,65,71,73,74,77,78,86,87,94,95,99,102,104,107,110–113,116,118–121,123,126,128

### Knowledge

As noted in Chapter 1, studies examining the effectiveness of CHW interventions are based in part on theories of individual behavior change. Studies relying on social cognitive theory as a model of individual behavior change anticipate that participants in CHW interventions will change their behavior based on knowledge they gain by observing and learning from CHWs.

Very few studies presented evidence on the effect of CHW interventions on the knowledge of participants (Table 37). The five studies reporting information on knowledge together provide (a) moderate strength of evidence that CHW interventions improve the knowledge of participants on disease prevention16,117,127 and cancer screening17,18,109 compared with other alternatives, (b) low strength of evidence that CHW interventions improve knowledge of label reading compared with usual care, but (c) insufficient evidence for knowledge of other issues related to the clinical or self-management of diabetes, such as dietary knowledge, appropriate diet, frequency of checking blood sugar, understanding the need for eye doctor visits, knowledge of how diabetes affects the body (eye, kidney, nerve, cardiovascular problems), or understanding insulin or other medication.27

Table 37 Effect of CHW interventions on knowledge: strength of evidence

Number of Studies; # of Subjects | Risk of Bias Design/Quality | Consistency | Directness | Precision | Other Modifying Factors (Intensity, Confounding) | Results | Overall Strength of Evidence
Health promotion and disease prevention: disease prevention
2; 6,841^16,117,127^ | Medium 1 RCT, 1 prospective cohort/fair | Consistent | Indirect | Precise | Absent | Favors CHW intervention vs. print or no intervention (for improved knowledge of label reading, knowledge of fat in diet, and knowledge of where to obtain free condoms) | Moderate
Cancer screening
2; 1,788^17,18,109^ | Low 2 RCTs/1 good, 1 fair | Consistent | Indirect | Imprecise | Absent | Favors CHW vs. media or mail | Moderate
Chronic disease management: diabetes mellitus
1; 150^27^ | Medium 1 RCT/fair | Consistency unknown (single study) | Direct | Not reported | Absent | Favors CHW intervention vs. usual care plus pamphlets (for knowledge of label reading) | Low

CHW, community health worker; RCT, randomized controlled trial.

This literature did not compare CHWs with a comprehensive range of usual care providers. Therefore, we cannot conclude that CHWs outperform all alternatives in improving participant knowledge. Nevertheless, for the much smaller subset of comparators and outcomes included in this literature, the studies together suggest that CHW interventions can improve participant knowledge when compared with alternative approaches such as no intervention, media, mail, or usual care plus pamphlets.

We found no evidence on knowledge for all other clinical topics and subdomains, as documented above in Table 36. The absence of data on the vast majority of clinical concerns that investigators in this field sought to study (as listed in Table 36) suggests that researchers may have elected to give priority to collecting and publishing data on health outcomes and health care utilization data rather than intermediate outcomes such as knowledge.

### Behavior

Twenty-two studies reported on the effect of CHW interventions on participant behavior. The evidence for workplace safety, diabetes mellitus, and the use of bedding encasements for asthma, from five studies, suggests that CHW interventions can change participant behavior in the desired direction when compared with alternatives such as a community intervention, a lower-intensity CHW intervention, and usual care combined with a pamphlet (Table 38).17,18,88–92,96,97,100,109,124,126 The strength of evidence is moderate for the use of bedding encasements for asthma and low for workplace safety and diabetes mellitus.

Table 38 Effect of CHW interventions on behavior: strength of evidence

Number of Studies; # of Subjects | Risk of Bias Design/Quality | Consistency | Directness | Precision | Other Modifying Factors (Intensity, Confounding) | Results | Overall Strength of Evidence
Health promotion and disease prevention: health promotion – Latina health
1; 357^64,65^ | High 1 RCT/poor | Consistency unknown (single study) | Indirect | Not reported | Present | No difference between CHW intervention and tailored or off- the-shelf interventions | Low
Health promotion and disease prevention: disease prevention
5; 1,125+12 churches16,67, 105,107,118,119,127 | Medium 5 RCTs/3 fair, 2 poor | Inconsistent | Indirect | Imprecise | Present | Mixed results: 3 of 5 studies favor CHW intervention vs. control (no intervention, combination of interventions, media/print) | Low
Injury prevention: home safety
2; 2,909^101,102^ | Medium 2 RCTs/1 fair, 1 poor | Inconsistent | Indirect | Precise | Present | No difference between CHW and health professional or no intervention | Low
Injury prevention: workplace safety
1;786^126^ | High 1 prospective cohort/poor | Consistency unknown (single study) | Direct | Imprecise | Present | Favors CHW over community intervention | Low
Maternal and child health: environment conducive to child well-being
3; 1,052^75,76,78,84,128^ | Medium 3 RCTs/2 fair, 1 poor | Inconsistent | Direct | Imprecise | Present | Mixed results: Most with no difference between CHW & control; some benefit to CHW over no intervention | Low
Cancer screening: planned use of screening tests
2; 1,612^63,116^ | Medium 1 RCT, 1 cohort/1 fair, 1 poor | Inconsistent | Indirect | Imprecise | Present | Mixed results: 1 study shows benefit in CHW arm vs. usual, other shows no difference vs. no intervention | Low
Cancer screening: breast self-examination
5; 3,798^61,62,108,110–112,116,125^ | Medium 2 RCTs, 3 cohorts/3 fair, 2 poor | Inconsistent | Direct | Imprecise | Present | Mixed results: 2 of 5 studies show benefit of CHW vs. alternative (mail or minimal CHW), 3 of 5 show no difference vs. delayed or no intervention | Low
Chronic disease management: diabetes mellitus
2; 213^88–92,124^ | Medium 2 RCTs/fair | Consistent | Indirect | Precise | Absent | Favors CHW intervention vs. usual care plus newsletter | Low
Chronic disease management: asthma, use of bedding encasements
2; 572^96,97,100^ | Low 2 RCTs/1 good, 1 fair | Consistent | Indirect | Precise | Absent | Favors CHW vs. less intense CHW arm or delayed CHW arm | Moderate
Chronic disease management: asthma, other behaviors (smoking cessation, removal of mold)
2; 572^96,97,100^ | Low 2 RCTs/1 good, 1 fair | Inconsistent | Indirect | Imprecise | Absent | No difference between CHW vs. less intense CHW arm or delayed CHW arm | Low

CHW, community health worker; RCT, randomized controlled trial.

The evidence for disease prevention, improving the environment for child well-being, planned use of cancer screening tests, and breast self-examination, from 14 studies, is mixed. Some studies demonstrate a statistically significant benefit from the CHW arm, but others show no significant differences.16,61–63,67,75,76,78,84,105,107,108,110–112,116,118,119,125,127,128 The strength of evidence for these outcomes is low.

The evidence for health promotion among Latinas, injury prevention at home, and smoking cessation to reduce asthma, from five studies, failed to demonstrate that CHW interventions resulted in statistically significant different outcomes than alternatives; the strength of evidence for these outcomes is low.64,65,96,97,100–102 We found no evidence to evaluate the effectiveness of CHW interventions for all other clinical concerns described in Table 36.

Together these studies suggest that CHW interventions can, in some instances, yield greater positive changes in participant behavior than a range of alternatives (including no intervention, community intervention, usual care plus a newsletter, media/print, a less intense or delayed CHW arm, or a combination of interventions). In other instances, CHWs interventions provided no statistically different benefit when compared with a range of alternatives, in the context of improvements in all arms. When the alternative requires greater resource allocation, as with the use of health professionals, the absence of a statistically significant difference may support the use of CHWs.101

The absence of consistent evidence showing that CHW interventions provide greater benefit when compared with alternatives may be explained in part by either the inadequacy of the CHW approach in changing some behaviors or other factors such as limitations of study design and the Hawthorne effect. Regarding the effectiveness of the CHW approach, CHWs may be more effective at changing behaviors that are relatively easy to adopt (such as the use of bedding encasements provided through the intervention) and less effective in changing behaviors that may require additional support (such as smoking cessation) or more resources (such as the removal of mold or changing home environments). Study design considerations such as the choice of lower-intensity CHW interventions or the use of other fairly intensive alternatives (or both situations) may not produce statistically significant differences between the CHW arm and the alternative; the absence of differences may be further compounded by inadequate power in many of these studies. As for the Hawthorne effect, when CHWs collect or report on outcomes in all study arms (as was often the case in these studies), this lack of blinding of outcomes assessors can induce an observation-related improvement in performance.

### Satisfaction

CHW interventions are often expected to prompt individual and social change and thereby reduce health disparities in either access to care or outcomes of care (or both). An indirect measure of improved access to the health care system is the participant’s satisfaction with care. A single study, focusing on mental health among the homeless, found no differences between study arms in participant satisfaction; the strength of evidence for this outcome is low (Table 39).

Table 39 Effect of CHW interventions on participant satisfaction: strength of evidence

Number of Studies; # of Subjects | Risk of Bias Design/Quality | Consistency | Directness | Precision | Other Modifying Factors (Intensity, Confounding) | Results | Overall Strength of Evidence
Chronic disease management: mental health
1;165^120,121^ | High 1 RCT/poor | Consistency unknown (single study) | Direct | Not reported | Present | No difference between CHW intervention and control | Low

CHW, community health worker; RCT, randomized controlled trial.

We found no evidence to evaluate the effectiveness of CHW interventions for the other 19 other clinical concerns described in Table 36. We note that our exclusion of studies without comparison arms may have excluded program evaluations that examined participant satisfaction in greater detail.

### Health Outcomes

The literature examined CHW effectiveness on a range of outcomes. Of the 53 studies, 27 reported specifically on health outcomes (Table 40).

Table 40 Effect of CHW interventions on health outcomes: strength of evidence

Number of Studies; # of Subjects | Risk of Bias Design/Quality | Consistency | Directness | Precision | Other Modifying Factors (Intensity, Confounding) | Results | Overall Strength of Evidence
Health promotion and disease prevention: pediatric immunizations
3; 5,406^68–72^ | Medium 2 RCTs, 1 cohort/1 good, 1 fair, 1 poor | Inconsistent | Direct | Imprecise | Present | Mixed results: 2 of 3 studies favor CHW intervention vs. control; 1 shows no difference between CHW interventions and no intervention | Low
Health promotion and disease prevention: disease prevention
1; 294^16,127^ | Medium 1 RCT/fair | Consistency unknown (single study) | Direct | Not reported | Absent | No difference between CHW intervention and print intervention (for change in body mass index) | Low
Maternal and child health: prenatal care and perinatal outcomes
5; 3,389^71,77,79, 83,86,87^ | High 2 RCTs, 3 cohorts/2 fair, 3 poor | Inconsistent | Some direct, some indirect | Imprecise | Present | Mixed results, between CHW and professionals or no intervention or usual care | Low
Maternal and child health: child development
4; 1,664^75,76,78, 80–83,128^ | Medium 3 RCTs, 1 cohorts/3 fair, 1 poor | Inconsistent | Direct | Imprecise | Present | Mixed results: 2 studies show some benefit for CHW vs. no intervention or health professional, 2 show no difference between CHW and health professional | Low
Maternal and child health: environment conducive to child well-being
7; 2,299^67,68,73, 74,78,84,85,128^ | Medium 7 RCTs/4 fair, 3 poor | Inconsistent | Mostly indirect | Imprecise | Present | Mixed results: 5 studies show no benefit for CHW over alternatives, 2 show benefit of CHW arm vs. usual care or health professional | Low
Chronic disease management: diabetes mellitus
4; 479^27,88–93,124^ | Low 4 RCTs/fair | Inconsistent | Direct | Imprecise | Absent | Mixed results: 2 of 4 studies found CHW more effective than usual care in decreasing mean HgbA1c, 2 found no difference | Low
Chronic disease management: hypertension
3; 2,823^23,94,95,98,99^ | Medium 2 RCTs, 1 cohort/1 fair, 2 poor | Consistent | Direct | Precise | Present | No difference between CHW intervention and CHW in a lesser capacity | Low
Chronic disease management: back pain
1; 255^114^ | Medium 1 RCT/fair | Consistency unknown (single study) | Direct | Not reported | Absent | Favors CHW intervention vs. usual care plus a book for Roland score at 6 months and worry score at 12 months; no difference in Roland score at 12 months | Moderate
Chronic disease management: mental health
1; 165^120,121^ | High 1 RCT/poor | Consistency unknown (single study) | Direct | Not reported | Present | No difference between CHW intervention and usual care (health professionals) | Low
Chronic disease management: asthma symptoms
2; 572^96,97,100^ | Low 2 RCTs/1 good, 1 fair | Inconsistent | Direct | Imprecise | Absent | Mixed results: 1 favors CHW vs. delayed intervention; no difference between CHW and less intense intervention | Low
Chronic disease management: asthma, caregiver psychosocial outcomes
2; 572^96,97,100^ | Low 2 RCTs/1 good, 1 fair | Consistent | Direct | Precise | Absent | Favors CHW vs. less intense CHW arm or delayed intervention | Moderate

CHW, community health worker; RCT, randomized controlled trial.

The evidence for back pain and for improving psychosocial outcomes among caregivers of children with asthma, from three studies, provides moderate strength of evidence that CHW interventions improve health outcomes when compared with either a lower-intensity CHW intervention or a delayed-intervention control group.96,97,100,114

The evidence for seven clinical areas and subdomains—pediatric immunizations, prenatal care and perinatal outcomes, child development, environment conducive to child well-being, diabetes, mental health, and asthma symptoms—from 22 studies, is mixed. Some studies suggested that CHW interventions are more effective than alternatives (including no intervention, usual care, and nurses), but others produced no differences between CHW interventions and alternatives.27,67–93,96,97,100,124,128

For disease prevention, hypertension, and mental health, the evidence from five studies suggests no difference between CHW interventions and alternative approaches, including the use of CHWs in a lesser capacity, nurses, and print materials; the strength of evidence for these outcomes is low.16,23,94,95,98,99,120,121,127 We found no evidence to evaluate the effectiveness of CHW interventions for other clinical concerns described in Table 36.

Our overall assessment for the effect of CHWs on health outcomes is similar to our assessment of their effect on behavior change. Together these studies show that CHW interventions can have a greater effect on health outcomes than certain alternative options such as no intervention, usual care, and nurses, but these findings are not consistent across all studies; several studies find no statistically significant benefit to the CHW arm when compared with alternative approaches. The strength of evidence for the reported absence of differences is therefore low. As with our summary assessment of the effect of CHW interventions on change in participant behavior, we believe that in the context of comparable gains in study arms and the absence of statistically significant differences among study arms, the choice of CHW interventions may be reasonable when the comparator is a high-resource alternative.

### Health Care Utilization

More than half of the 53 identified studies (30 studies) reported on health care utilization (Table 41).

Table 41 Effect of CHW intervention on health care utilization: strength of evidence

Number of Studies; # of Subjects | Risk of Bias Design/Quality | Consistency | Directness | Precision | Other Modifying Factors (Intensity, Confounding) | Results | Overall Strength of Evidence
Health promotion and disease prevention: health promotion – Latina health
1; 103^66^ | Medium 1 RCT/fair | Consistency unknown (single study) | Direct | Imprecise | Present | No difference between CHW and mail | Low
Health promotion and disease prevention: disease prevention
1; 421^105^ | Medium 1 RCT/fair | Consistency unknown (single study) | Direct | Precise | Absent | Favors CHW intervention vs. no intervention | Moderate
Maternal and child health: prenatal care and perinatal outcomes
1; 145^79^ | Medium 1 RCT/fair | Consistency unknown (single study) | Indirect | Imprecise | Absent | Favors CHW vs. health professional | Low
Maternal and child health: Environment conducive to child well-being
1; 730^78,128^ | High 1 RCT/poor | Consistency unknown (single study) | Indirect | Imprecise | Present | No difference between CHW intervention and routine clinical care | Low
Cancer screening: Pap smears
6; 4,366^17,18,61–63,110–112,125^ | Low 5 RCTs, 1 observatio nal/1 good, 4 fair, 1 poor | Inconsistent | Direct | Imprecise (when reported) | Present | Mixed results: 3 of 6 studies show some difference between CHW and minimal CHW, media, direct mail, and usual care, 3 show no difference between CHW and mail or no intervention | Low
Cancer screening: mammography
11; 17,401^15,17–22^,59– 62,103,104,108,110–113,116,125,177 | Medium 6 RCTs, 5 observational studies/2 good, 4 fair, 5 poor | Consistent | Direct | Precise (when reported) | Present | 8 of 11 studies favor CHW vs. no intervention, mail, print, or minimal CHW; 3 show no difference CHW and no- intervention control | Moderate
Cancer screening: clinical breast examination
4; 3,386^61,62,110–112,116,125^ | High 2 RCTs, 2 observational/2 fair, 2 poor | Consistent | Direct | Imprecise | Present | No difference between CHW intervention and mail, CHW in lesser capacity and no intervention | Low
Cancer screening: colorectal cancer screening
2; NR107, 78^106^ | High 2 RCT/1 fair, 1 poor | Inconsistent | Direct | NR | Present | Mixed results, 1 study favors CHW versus usual care, the other shows no difference between CHW intervention and controls (no- intervention control, tailored print and video) | Low
Chronic disease management: hypertension
1; 722^123^ | High 1 cohort/poor | Consistency unknown (single study) | Direct | Not reported | Present | Favors CHW intervention vs. no intervention | Low
Chronic disease management: infectious diseases
1; 244^122^ | Medium 1 RCT/fair | Consistency unknown (single study) | Direct | Precise | Absent | Favors CHW intervention vs. control group given bus tokens, but monetary incentive was more effective than CHW or control given bus tokens | Moderate
Chronic disease management: mental health
1; 165^120,121^ | High 1 RCT/poor | Consistency unknown (single study) | Indirect | Not reported | Present | No difference between CHW intervention and usual care (health professionals) | Low
Chronic disease management: asthma
2; 572^96,97,100^ | Low 2 RCTs/1 good, 1 fair | Consistent | Direct | Precise | Absent | Favors CHW vs. less intense CHW arm or delayed intervention | Moderate

CHW, community health worker; RCT, randomized controlled trial.

Fifteen studies provide moderate strength of evidence that CHW interventions increase appropriate health care utilization for disease prevention, mammography, infectious diseases, and asthma when compared with a range of alternatives such as no intervention, mail, print, or a less intense CHW arm. 15,17–22,59–62,96,97,100,103–105,108,110–113,116,122,177 Two studies provide low strength of evidence that CHW interventions provide benefits in health care utilization when compared with nurses for prenatal and perinatal care and usual care for hypertension.79,123

For Pap smears, six studies provide mixed evidence. Some studies report statistically significant benefit for the CHW arm but others find no significant differences; the strength of evidence for this outcome is low.17,18,61–63,110–112,125 For health promotion among Latinas, child well-being, clinical breast examination, colorectal cancer screening, and mental health, evidence from nine studies suggests that the CHW intervention and alternatives do not differ; the strength of evidence for these outcomes is low.61,62,66,78,106,107,110–112,116,120,121,125,128 We found no evidence to evaluate the effectiveness of CHW interventions for all other clinical concerns described in Table 36.

Together, these studies provide either low or moderate evidence that CHW interventions increase some appropriate health care utilization (e.g., more use of cancer screening tests, less use of emergency services) when compared with a range of alternatives for disease prevention, mammography, infectious diseases, and asthma. For other reported outcomes, however, the evidence is mixed or does not show a statistically significant benefit of the CHW arm. As with our discussion of results for participant behavior and health outcomes, we note that for some outcomes that had no statistically significant benefit of the CHW arm, the strength of evidence is low; the reasons are similar to those discussed above and include study design, choice of comparators, and the Hawthorne effect.

### Applicability of Findings about Outcomes

Our analysis of applicability reviewed studies by clinical context along five dimensions: population, intensity of treatment, choice of comparator, outcomes, and timing of followup. We summarize these findings across all studies below.

Population. CHW interventions were generally conducted in underserved populations and were not overly restrictive in their inclusion criteria. We note, however, that individual studies tended to focus on a specific subset, such as low-income Latinas or inner-city African-Americans, of the larger and diverse group of the underserved. As a result, the intervention effects are likely to be applicable to the population studied, but the findings cannot be extrapolated as being relevant to all underserved populations. In particular, the applicability of these studies to low-income populations that would not qualify for Medicaid, but could not afford health insurance, is unclear.

Intensity of the treatment. As noted in earlier chapters, the studies in this review were predominantly high intensity (51 percent) or moderate intensity (34 percent) rather than low intensity (15 percent). We found CHW interventions for Pap smears to be more effective than comparison efforts (such as no intervention, media, print, community interventions, and usual care) only in the relatively limited circumstances of low- and moderate-intensity interventions rather than high-intensity interventions. We found no clear evidence of variation in the effectiveness of CHW interventions by intensity of the intervention for any other outcomes. The absence of consistent evidence supporting the use of high-intensity interventions and the limited applicability of these more costly approaches to a larger population suggests that future interventions may be well served if they re-examine assumptions that high-intensity interventions work better than moderate- or low-intensity interventions.

Choice of comparator. The wide variation in the choice of comparators across all included studies reflects the immense array of options for health care in the United States. Although investigators often did justify or explain their choices of comparator, the selections often reflected a reasonable range of usual care options for the appropriate subpopulations, such as a health professional alternative for children with chronic diseases or no intervention for home safety. The diversity of these comparators does, however, limit the generalizability of our findings significantly. Our assessment of effectiveness of the CHW arm (or lack thereof) can be interpreted only in the context of the specific comparators in the literature; these findings cannot be said to be meaningful for a comprehensive range of comparators or even for usual care.

Outcomes. Forty-two percent of the 53 studies reported on behaviors, 51 percent on health outcomes, and 57 percent on health care utilization. The focus on these outcomes was appropriate and applicable to settings other than those selected for the study. The choice of outcome measures was rarely comparable across studies. The variations in outcome measures and choice of comparators precluded quantitative syntheses.

Timing of followup. Included studies by and large had an appropriate length of followup for examining the effect of the CHW intervention. Some outcomes, such as developmental outcomes for children in the relatively short term (12 months to 4 years), may not always have a high correlation with long-term health outcomes, but we regard them as appropriate for the intervention.

### Summary Findings by Clinical Context

Health promotion and disease prevention. Eleven studies addressed health promotion and disease prevention, including pediatric immunizations,68–72 cardiovascular disease,105,118,119 diabetes prevention,16,127 HIV prevention,117 second-hand smoke exposure,67 colorectal cancer prevention,107 and general preventive care.64–66 Two studies on disease prevention found that CHW interventions were more effective in changing knowledge than print or no intervention.16,117,127 Results for CHW interventions on behavior outcomes were mixed, with half of the studies favoring CHW intervention versus control groups consisting of no intervention, media/print, or a combination of interventions.16,105,118,119,127 None of the studies evaluated satisfaction outcomes. Results for CHW interventions on health outcomes, available from four studies,16,68–72,127 were also mixed.

The results suggest that CHW interventions can serve as an effective means of improving knowledge outcomes and possibly other outcomes related to preventing disease in underserved, minority populations.

Injury prevention. Three studies assessed injury prevention measures: two focused on home injury prevention101,102 and one considered workplace injury prevention.126 The workplace study found improvements in behavior associated with CHW interventions when compared with a minimal community intervention.126 One home injury prevention study found mixed results with CHW interventions showing statistically significant benefit in some measures but controls (with no intervention) showing statistically significant benefit over CHW interventions for other measures.102 The other home injury prevention study showed no significant difference in behavior between CHW interventions and health care professional. 101 None of the studies assessed direct health outcomes. The mixed results preclude any firm conclusions regarding the benefit of CHW interventions for injury prevention.

Maternal and child health. Fifteen studies meeting our inclusion criteria involved primarily maternal and/or child health.67,71–87,128 Of these, 12 focused exclusively on potentially vulnerable populations (e.g., racial or ethnic minorities, recent immigrants, low-income families, inner-city residents).67,68,71,72,75–77,79–82,84–87 Another three targeted families identified as high risk for child maltreatment.73,74,78,128 Pregnant women were part of the target population for eight studies.71,72,77,79–83,86,87 One study each addressed pregnant women with phenylketonuria (PKU),83 children with failure to thrive,75,76 and children with “chronic disease” (not otherwise characterized).85

Statistically significant benefit of CHWs over standard care was shown most prominently in the rapidity of metabolic control for mothers with PKU and in the mental development of infants of mothers with PKU.83 CHW interventions were associated with a greater likelihood of initiating breastfeeding among African Americans, more frequent use of nonviolent discipline methods by parents, and higher parenting efficacy scores than either video intervention or no intervention. The study of infants with failure to thrive found a decline in cognitive and motor development among infants and an increase in depressive symptoms among mothers over time in both arms of the study; however, CHWs were significantly associated with attenuation in the decline in cognitive and motor development of infants with failure to thrive and in the increase in depressive symptoms among mothers when compared with no intervention.75,76 No significant advantage to CHW intervention was seen for improvements in incidence of low birth weight, presence of neonatal or infant health problems, language development, maternal stress or self-esteem, continuation of breastfeeding beyond 1 week, tobacco exposure for children of smokers, continued drug use among mothers with known prior drug use, growth of children with failure to thrive, or incidence of child maltreatment when compared with nurse interventions, multidisciplinary specialty clinical care, video or print intervention, routine health care, or no intervention.

Most studies involving CHWs for maternal and child health were concerned with high-risk populations. For maternal and child health, CHWs appear to be most beneficial when addressing existing health conditions instead of potential conditions, i.e., primary prevention. Eight of the 15 studies evaluated reported statistically significant benefit to CHWs compared with nurse interventions, multidisciplinary specialty clinical care, video or print intervention, routine health care, or no intervention. CHWs have not yet been shown to improve key health outcomes relating to maternal and child health such as prematurity, low birth weight, sustained breastfeeding, or child maltreatment relative to other alternatives such as video or print intervention, routine health care, or no intervention. The lack of such findings suggests either that further research is needed to demonstrate benefits or that the use of CHWs in this domain actually does not produce greater benefits than the use of existing approaches.

Cancer screening. Fifteen studies that examined outcomes of CHW interventions for improving breast, cervical, or colorectal cancer screening met inclusion criteria for this systematic review.15,17–22,59–63,103,104,106–113,116,125 All studies focused on minority or underserved communities. With the exception of two studies on colorectal cancer screening that included both men and women, all studies focus on increasing the rates of breast and cervical cancer screening among women.

Together, the 15 studies suggest limited evidence of improvement in knowledge in the CHW arm compared with groups receiving alternative approaches such as media or mail. Findings were conflicting about the effect of CHWs on planned or actual behavior changes, specifically breast self-examination, when compared with no intervention, delayed intervention, mail, minimal CHW, or usual care. The volume of evidence on health outcomes is limited; the quality and design of the studies limits the interpretation of available evidence.

Regarding health care utilization, our findings from limited evidence suggest that CHW interventions are not effective in comparison with other alternatives (such as no intervention, mail, tailored print and video, and minimal CHW) in raising the rates of clinical breast examination or colorectal cancer screening. More substantial evidence exists on Pap smears and mammography. It suggests that CHWs are at least as effective as alternative steps (such as mail or lower-intensity CHW interventions) in improving Pap smear rates; they are more effective than alternatives (such as no intervention, media, print, community interventions, and usual care) only in limited circumstances of low- and moderate-intensity interventions rather than high-intensity interventions. Studies demonstrated significantly greater improvements in the CHW groups than in comparison groups (no intervention, mail, print, or minimal CHW) in either the entire sample or in low-income, minority, or other underserved subsamples.

CHW interventions were more effective than alternatives (ranging from usual care to a less intense CHW arm) for increasing the appropriate use of Pap smears and mammograms, for specific subpopulations and subtypes of interventions. They were not, however, more effective than alternatives for increasing the utilization of breast self-examination, clinical breast examination, or colorectal cancer screening. CHWs can serve as a means of improving utilization of Pap smear tests and mammograms for underserved populations; the effectiveness of CHWs for other outcomes requires further research.

Chronic disease management. Thirteen studies addressed disease management for several diagnoses: diabetes mellitus,27,88–93,124 hypertension,23,94,98,99,123 asthma,96,97,100 back pain,114 mental health,120,121 and tuberculosis.122 Only one of these studies addressed knowledge of diabetes and found an improved score in the CHW group compared with the group receiving usual care plus educational pamphlets.27

Two CHW interventions on diabetes88–92,124 and both asthma studies96,97,100 addressed behavior changes; for diabetes, they favored CHW interventions over usual care and a less intense CHW arm, and for asthma, they favored CHWs with respect to improving use of bedding encasements but not smoking cessation. Only the study in mental health addressed satisfaction outcomes; it did not demonstrate a difference between the CHW and the control groups.120,121

Several studies investigated various health outcomes. In diabetes management, two of four studies found that a CHW intervention was more effective than usual care in decreasing HgbA1c.27,93 None of the four studies addressing hypertension management showed a significant difference in blood pressure control between groups.23,94,98,99,123 Both asthma studies demonstrated that CHW interventions were effective in reducing unscheduled health care services, psychological outcomes, and behavior changes between groups;96,97,100 however, symptom measures improved within the CHW and comparison groups but did not differ significantly between the groups.

In four of five studies on chronic disease management, a CHW intervention was more effective than either usual care or a less intense CHW arm in improving health care utilization for hypertension, mental health, and asthma.96,97,100,122,123 The fifth study found that CHWs were less effective than a monetary incentive in increasing adherence to clinic appointments among tuberculosis-infected patients.

For chronic disease management, the majority of CHW interventions failed to show greater improvement in health outcomes than were observed for usual care. The exception is asthma care, for which CHWs were effective for many outcomes. Further research is necessary to determine the role of CHWs in chronic disease management.

## Cost-Effectiveness of Community Health Worker Interventions (KQ 3)

Only six studies that we identified in the literature provided economic analyses of CHW interventions.17,22,75,80,96,121 Our analysis does not include three other studies of CHW interventions that reported information on intervention program costs but found that CHW interventions were ineffective or less effective than the baseline care approach.64,67,69,70

All six studies included for this KQ estimated intervention program costs, but not all reported the specific components of those costs or the year for which costs were estimated. Four of the studies performed economic analyses beyond program cost estimation to examine program costs in relationship to effectiveness. The two cancer screening studies both reported estimates of the cost per additional mammography screening. Although the common measures reported across these two studies suggest that comparisons might be straightforward, differences in the targeted populations nonetheless hinder comparisons of cost-effectiveness ratios across the studies. In particular, the low-intensity intervention targeted women regardless of their adherence to screening guidelines; however, the high-intensity intervention targeted only nonadherent women. The other two studies that performed additional economic analyses focused on estimating potential reductions in costs of both health care and social services attributable to the CHW intervention.

None of the CHW intervention evaluations that included an economic analysis reported a standard measure of costs per quality-adjusted life year saved as recommended in recent guides for performing economic evaluations.130,131, 2003 One study did report on the costs per life-year saved of the CHW intervention, which is useful for comparing the intervention costs with those for other life-saving interventions, but that study provided the intervention both to women who had previously obtained mammography in line with mammogram screening guidelines and to women who had not; this approach biases the cost-effectiveness results in favor of the intervention, even when CHW time was valued using average wage rates.22 The lack of reporting on intervention costs and cost-effectiveness according to standardized and commonly accepted measures makes it challenging to compare economic outcomes across CHW intervention studies; it also makes it even more complicated to compare cost-effectiveness between CHW interventions and non-CHW health care interventions currently being reported in the literature.

In sum, limited evidence is currently available on the cost-effectiveness of CHW interventions for 7 of the 20 clinical contexts and subdomains we have examined in this systematic review (Table 42). For all the other clinical concerns described in Table 36, we found no evidence. Until better information is made available, assessing whether CHW interventions are a cost-effective alternative to clinical interventions to promote health and prevent disease is difficult, if not impossible.

Table 42 Cost and cost-effectiveness of CHW interventions: strength of evidence

Number of Studies; # of Subjects | Risk of Bias Design/Quality | Consistency | Directness | Precision | Other Modifying Factors (Intensity, Confounding) | Results | Overall Strength of Evidence
Health promotion and disease prevention: pediatric immunizations
1; NA69,70 | --- | --- | --- | --- | --- | Not evaluated because of lack of evidence of intervention effectiveness | ---
Health promotion and disease prevention: health promotion – Latina health
1; NA64 | --- | --- | --- | --- | --- | Not evaluated because of lack of evidence of intervention effectiveness | ---
Maternal and child health: child development
2;130^75^ 630^80^ | Low 2 RCTs | Consistent | Direct | Imprecise | Absent | Cost for CHW home visitation program was lower than for nurse home visitation program; no comparison of costs to program effectiveness | Low
Maternal and child health: environment conducive to child well-being
1; NA67 | --- | --- | --- | --- | --- | Not evaluated because of lack of evidence of intervention effectiveness | ---
Cancer screening: mammography promotion
2; 851^17^ 1,443^22^ | Moderate 2 RCTs | Consistent | Direct | Imprecise | Absent | Cost per additional mammogram is not a standardized measure that can be compared to the cost- effectiveness of other interventions | Low
Chronic disease management: mental health
1; 165^121^ | High 1 RCT | Consistency unknown (single study) | Direct | Imprecise | Absent | Intervention costs slightly lower for CHW arm than for traditional assertive community treatment; inconclusive results on impact of CHW on net program costs | Low
Chronic disease management: asthma
1;170^96^ | Low 1 RCT | Consistency unknown (single study) | Direct | Imprecise | Absent | Larger urgent care cost reductions for high-intensity CHW group as compared to low-intensity CHW group. | Moderate

CHW, community health worker; RCT, randomized controlled trial.

## Training of Community Health Workers (KQ 4)

We found only nine studies meeting our inclusion criteria that described the training of CHWs.137,141,143,147,150,155,169, 148,149,176 Our inclusion criterion required the evaluation of skills before and after training; all included studies reported evidence of improvement in knowledge or skills. Few studies reported on training for cultural competence, recruitment and retention process skills, intake and assessment, and protocol delivery; studies generally focused on aspects of training relevant to the health concern.

Such data are useful for future studies on the same clinical topic, but the failure to report on common elements such as cultural competence, recruitment and retention process skills, intake and assessment, and protocol delivery presents a roadblock to identifying critical elements of a standardized curriculum applicable to all CHWs. Whether studies routinely conduct such training and do not report on them is unclear from the studies that we identified.

No study reported on the effects of CHW training on health outcomes. Practitioners and policy makers seeking to institutionalize CHWs may seek to understand what measures of CHW activities best assess the effectiveness of their contributions to improved health outcomes and further, how to incorporate those elements into training curricula. As seen from the limited evidence available to answer KQ 4b, studies do not presently report sufficient information to answer this question. The question of how to tailor CHW training to improve health outcomes is a significant gap for future studies to address.

Two studies reported certification associated with their curricula. One study, focusing on tobacco cessation, offered three levels of certification: introductory (“Basic Skills to Stop Using Tobacco”), intermediate (“Treatment Specialist”), and advanced (“Leave the Addiction”).150 A second study, on cancer education, provided a certificate of completion at the end of the training, but it gave no further details.143

Several studies reported on the availability of their curricula for future projects. These included topics related to safe manufacture of queso fresco,155 tobacco cessation,150 breast cancer education,137 heart disease and stroke,147 and heart healthy behaviors among Latinos.149

We note that the nine studies identified as eligible for this KQ represent a small fraction of all studies reporting on training. Other ineligible studies did not evaluate pre- and posttraining skills or knowledge: many were purely descriptive of training programs.134,153,154,161,170,171,175 Among the ineligible studies that provided a critical appraisal or evaluation of the training program without pre- and posttraining results, several limited the assessment of the knowledge or skills of the CHW to the posttraining period only, without a pretest.139,142,145,156,160,167,173,176 A substantial number of other ineligible studies evaluated the training or curriculum based on feedback from designers, trainers, or other stakeholders.132,135,137,138,140,141,151,152,157–160,162–169,172–174,176 These studies could not inform our key question on training; thus, we excluded them from the systematic review proper, but we note them here to be helpful to readers who may wish to pursue these topics further.

## Limitations of this Review

### Limitations of the Evidence Base

Reporting. Our ability to draw conclusions on the effectiveness of CHW interventions is limited by the relative paucity of detail on specific elements of the interventions. Studies inconsistently adhered to reporting standards such as STROBE178 and CONSORT,179 making critical appraisal of internal validity and assessment of applicability challenging. In particular, many studies did not report on the intensity of the intervention (the number and length of sessions and the time period of interaction with clients), the existence of protocols governing the intensity of intervention, or fidelity to such protocols. CHW interventions represent an opportunity to translate effective interventions into a variety of community settings; the absence of information on fidelity limits their translation. The limited available information on protocol also results in little usable data on training of CHWs.

Choice of appropriate comparators. The evidence base is marked by great heterogeneity in comparators in addition to appreciable diversity in the CHW model itself. Although appropriate comparators can and should differ by the specific outcomes being addressed, studies often did not justify the choice of comparator(s), either on its own merits or in relation to usual care. For that reason, our conclusions regarding the effectiveness of CHWs are necessarily limited. We also note that a potential Hawthorne effect may exist for studies comparing variants of CHW interventions rather than CHW interventions with usual care: the effect of the more intense arm may have been diluted by a Hawthorne effect in the less intense arm, whereby observation by CHWs could improve outcomes (at least in the short term) in the latter case.

Study design. Many studies did not report a priori hypotheses about their primary outcomes or give details about their power calculations (if any were done). Limited sample sizes may have resulted in studies that were not powered to find a difference between “experimental” and “control” or “comparison” groups where one may in fact exist.

A further design limitation is the frequent reliance on CHWs for data collection of outcomes in all study arms. This practice can lead to potential bias on the part of the outcome assessor; when subjects are providing responses directly to the CHWs gathering data about outcomes, their information may be colored by social desirability on their part. Moreover, a potential Hawthorne effect in this situation cannot be ruled out, as noted above.

Appropriate adjustment for confounding. The evidence base is also limited by variations in the specific confounders and effect modifiers that investigators included or controlled for in their analyses. Omitting important confounders and effect modifiers, especially co-interventions in comparison arms, limits the interpretability and utility of the evidence from such investigations. Furthermore, using the studies that did account for confounders and effect modifiers is hampered by the lack of consistent definition and inclusion of key variables.

These deficiencies together appreciably limit the consistency and validity of the evidence. As a result, we found very few outcomes for which we were able to attribute at least a moderate strength of association, despite the relatively large body of evidence that we examined.

### Limitations of the Review

We limited our search to articles published in English, primarily for reasons of time and resources. We excluded studies with samples sizes less than 40. We also limited our review to the United States, so our review does not address the nature, outcomes, or cost-effectiveness of CHW interventions, or the training of CHWs, elsewhere, particularly in developing countries. However, whether CHWs in the United States have the same professional and sociodemographic characteristics as CHWs elsewhere is not well understood, so for purposes of this review, constraining the included studies to those done in the United States may not have influenced our findings much.

Our decision to include studies with comparison arms for KQs 1 and 2 likely reduced our yield of studies for knowledge, behavior, and satisfaction. We note, however, that studies reporting on knowledge, behavior, and satisfaction alone, without additional data on health outcomes, do not add to the evidence on the critical question of whether CHW interventions improve health outcomes.

For similar time and resource reasons, we did not conduct dual independent, blinded review of articles for abstraction of information into evidence tables. Instead, one reviewer performed the initial review, and a second reviewer examined that input and recommended changes or corrections when needed. These two reviewers reconciled any differences by consensus discussion. These procedures are generally in accord with the usual procedures for the RTI-UNC Evidence-based Practice Center. To enable us to address any systematic bias in our work that the above approach may have introduced, however, we did apply dual independent review for assessing the quality of individual articles and grading the strength of evidence.

The paucity of “similar” articles, for populations, patient characteristics, settings, and outcomes measured, precluded any efforts to pool findings statistically.

## Future Research Directions

The evidence on CHW interventions, although extensive, could benefit from future research. We discuss methodological improvements, design considerations, and substantive gaps below.

Methodological improvements. Future studies should consistently adopt four important steps: (1) give clear conceptual models that explain the expected mechanism of change initiated by the CHW intervention, (2) justify the choices of alternative or comparison steps; (3) specify a priori the primary outcomes to be measured; and (4) state hypotheses that build upon the conceptual framework and the choice of comparator. In addition, studies of CHW interventions should calculate required sample size to ensure that they are adequately powered and report on those power calculations.

Studies will also benefit from external evaluation of outcomes by investigators or data collection personnel blinded to the experimental and comparison groups rather than measurement of outcomes by CHWs. Such results would be less likely to be influenced by social desirability bias or other problems of internal validity of results. These benefits must be weighed against the practical difficulties of obtaining outcome data through external observers who (unlike CHWs) may not have a relationship with the community and may be viewed with a greater degree of suspicion.

A significant gap that future studies can address is adequate reporting of design, exposures, and outcomes. Adherence to standards such as STROBE178 and CONSORT179 will help to improve the strength of evidence provided by this literature. More generally, studies infrequently reported the gap between planned and actual protocol delivery; reporting the changes to protocol delivery is critical to a better understanding of how to scale up effective interventions.

Design considerations. CHW interventions will also benefit from the use of practical clinical trials. CHW interventions are examples of community-based research, which is vital for successful Type 2 translation – the adaption of evidence-based interventions to real-world settings.180–182 Representative participants, multiple and diverse settings, clinically relevant alternative interventions, and a focus on measures relevant to decision makers, which include cost, quality of life, reach, and adoption) can enhance the utility of CHW studies for translational research.183–185

The RE-AIM framework^††^–reach, effectiveness, adoption, implementation, and maintenance–provides practical guidance for the development of measures of public health impact for CHW interventions.186 Studies in our review focused on effectiveness, but they rarely provided quantitative assessments of these elements as measures of public health impact, despite their underlying reliance on models of community change in addition to individual change. Investigators may find the RE-AIM formulation helpful in providing an analytic or logic model by which to design and conduct their studies.

†† According to the RE-AIM framework186 (reach is defined as the absolute number, proportion, and representativeness of individuals who are willing to participate in a given initiative, intervention, or program. Efficacy or effectiveness is the impact of an intervention on important outcomes, including potential negative effects, quality of life, and economic outcomes. Adoption is the absolute number, proportion, and representativeness of settings and intervention agents (people who deliver the program) who are willing to initiate a program. At the setting level, implementation refers to the intervention agents’ fidelity to the various elements of an intervention’s protocol, including consistency of delivery as intended and the time and cost of the intervention. At the individual level, implementation refers to clients’ use of the intervention strategies. Maintenance is the extent to which a program or policy becomes institutionalized or part of the routine organizational practices and policies. Within the RE-AIM framework, maintenance also applies at the individual level. At the individual level, maintenance has been defined as the long-term effects of a program on outcomes after 6 or more months after the most recent intervention contact.

Substantive gaps. We identified several substantive gaps in the field that warrant further attention. They fall into several groups: (1) outcomes themselves, specifically knowledge and satisfaction; (2) clinical areas, including obesity prevention and colorectal cancer screening; (3) populations addressed, and specifically interventions for certain underserved populations; and (4) costs and cost-effectiveness analysis. We discuss these points in greater detail below.

Theoretical models underpinning CHW interventions postulate changes in knowledge as precursors to changes in behavior, health outcomes, or health care utilization. Our review uncovered surprisingly few studies that examined changes in knowledge. Although the focus on health outcomes and health care utilization is appropriate, additional evaluation of changes in knowledge would help to clarify the processes of change initiated by CHWs; such information would then aid investigators in refining aspects of their interventions that are not as effective as expected.

CHW interventions serve as a bridge to the health care system for the underserved and are expected to serve as a tool to reduce disparities in access to and quality of care. Improved satisfaction of participants with CHW interventions is a necessary first step to successful implementation of the intervention and eventual reduction in disparities. As with the literature on knowledge and evaluation of public health impact, single-arm studies may well report satisfaction in greater depth; more rigorous comparative studies almost uniformly do not report on satisfaction. Further investigation of satisfaction, in addition to the existing and appropriate focus on behaviors, health outcomes, and health care utilization, can help illuminate the effects of CHW interventions on health disparities.

Despite evidence of effectiveness and recommendations from a number of organizations including the US Preventive Services Task Force and the American Cancer Society, colorectal cancer screening uptake has been suboptimal. Roughly 60 percent of adults older than 50 report having been screened for colorectal cancer.187,188 In addition, even lower rates of screening have been reported in populations with high poverty rates189 and in racial and ethnic minorities, including Hispanic and nonwhite populations.190 We uncovered a single study focusing on CHW interventions for colorectal cancer;107 future research in this area may be fruitful in identifying successful strategies for increasing screening rates for this deadly condition.

Existing CHW interventions often focus on underserved populations defined by race, ethnicity, or geographic location. Underserved groups such as low-income populations who are ineligible for Medicaid (such as low-income undocumented immigrants) and therefore at higher risk of being uninsured or the elderly may also potentially benefit from studies of CHW interventions. Important conditions for such investigators include mental health problems, dementia including Alzheimer’s disease, and disabilities.

Future research on CHW interventions should focus on designing studies that prospectively collect data on program costs and effectiveness. Such work should aim to ensure that all necessary data are collected to perform and report on the cost-effectiveness or net costs of the CHW intervention as compared with baseline and alternative approaches. Program managers and local evaluators may benefit from checklists130,131 and step-by-step instructions for designing and performing economic evaluations of health care and community prevention interventions.191 The first step in collecting program cost data is to list the key program activities. The next steps are to determine the perspective of the cost analysis (e.g., program, patient, or societal perspective) and to list all the resources required to support each activity (e.g., labor, contracted services, materials and supplies, building space, donated resources). The final steps are to create a system and forms for the ongoing collection of program cost data. Many resources are available to guide program managers through each step of the cost data collection process, including checklists published in Gold et al., 1996^130^ and Haddix et al., 2003^131^ and forms available online in Honeycutt et al., 2006.^191^ These lists and forms can readily be adapted to capture all of the resources used or lost in providing CHW program activities. For example, to collect and analyze the costs of multiple arms of a CHW intervention program, a list of activities and resources to support the activities should be created for each arm. Based on these lists, worksheets should be developed specific to each intervention arm for use in prospective program data collection. After all data have been collected, costs for each intervention arm should be estimated and reported alongside other study outcomes. Economic evaluations of CHW interventions should also include sensitivity analyses to examine how uncertainty or variability in assumed costs or effectiveness affects program cost-effectiveness. For example, time spent by CHWs in delivering the intervention should be given a positive value in all economic evaluations of CHW interventions, but it may also be useful to explore the extent to which valuing time at the minimum wage makes the intervention look favorable as compared with valuing time at average wage rates for paid health care workers (e.g., licensed practical nurses or medical assistants).

In summary, future economic evaluations of CHW interventions should (1) evaluate the cost-effectiveness of the interventions as compared with baseline or alternative interventions, (2) model program outcomes to estimate the program’s full impact on life years or quality-adjusted life years saved to improve comparability of results, and (3) include sensitivity analyses to examine the impact of variability in economic inputs on the cost-effectiveness of CHW interventions. Using such standard approaches to evaluate CHW interventions will improve the utility and comparability of study results; thus, such approaches will also aid decision makers in determining which health promotion and disease prevention activities to support.

In the absence of consistent data on intervention costs, we created a pragmatic measure in this report to approximate the intensity of resources used for CHW interventions. Consistent data on costs in future studies will ideally provide the best information to evaluate intervention intensity. In the interim, further development and validation of pragmatic measures of resource intensity can help policy makers shape the specifics of CHW interventions to provide the most meaningful benefit for improved health outcomes.

## Conclusion

CHW interventions have the potential to address two fundamental imperatives in improving health care in the United States: the need to address substantial and persistent health care disparities and the need to translate more research into practice. CHWs, by virtue of their role as a bridge to the health care system, can help to disseminate widely efficacious interventions to populations that rarely benefit from health care advances.

Evidence about the effectiveness of CHWs relative to other choices for providing these types of health care and public health services is at best mixed. Some studies that we assessed demonstrated statistically significant benefits of the CHW approach compared with other choices; other studies showed conflicting results or no statistically significant differences between study arms. For the latter studies, one explanation is a lack of true benefit of the CHW arm relative to other choices. In addition, the choice of controls, including health professionals and CHWs in a lesser capacity, inadequate study power, and the Hawthorne effect may explain the lack of significant differences between CHWs and alternatives.

We found limited evidence that suggests that CHW interventions can improve participant knowledge when compared with alternative approaches such as no intervention, media, mail, or usual care plus pamphlets. We found mixed evidence for CHW effectiveness on participant behavior change and health outcomes: some studies suggested that CHW interventions can result in greater improvements in participant behavior and health outcomes when compared with various alternatives, but other studies suggested that CHW interventions provide no statistically different benefits. Low or moderate strength of evidence suggests that CHWs can increase appropriate utilization for some conditions or preventive services.

The literature showed mixed results of effectiveness when analyzed by clinical context. CHW interventions had the greatest effectiveness relative to alternatives for some disease prevention, asthma management, cervical cancer screening, and mammography screening outcomes. CHW interventions were not significantly different from alternatives for clinical breast examination, self-breast examination, colorectal cancer screening, chronic disease management, or most maternal and child health interventions. We found insufficient evidence to evaluate the cost-effectiveness of CHW interventions relative to other public health interventions.

Our review suggests that CHWs may serve as a means of improving outcomes for underserved populations for some health conditions, as described above. Other health concerns require further research that addresses methodological limitations of prior studies to evaluate fully the effectiveness of CHW interventions.