# Results

This chapter presents the results of our evidence review for the following four key questions (KQs): KQ 1, interaction of CHWs with participants; KQ 2, outcomes of community health worker (CHW) interventions; KQ 3, cost-effectiveness of CHW interventions; and KQ 4, training of CHWs and the relationship between CHW training and patient health outcomes. We note that KQ 3, on cost-effectiveness of CHW outcomes, is derivative of KQ 2 and is limited to studies demonstrating effectiveness. As noted in Chapter 2, a total of 53 studies qualified for inclusion for KQ 1 and KQ 2, 6 for KQ 3, and 9 for KQ 4.

Appendix C-1 provides the detailed evidence tables for KQs 1, 2, and 3. Appendixes C-2 and C-3 present individual quality ratings for randomized clinical trials (RCTs) and observational studies, respectively. Appendix C-3 provides detailed abstractions for KQ 4. All evidence tables are presented in alphabetical order by last name of the first author.

As noted in earlier chapters, an overall assessment of the effectiveness of CHW outcomes requires evaluation of sources of heterogeneity, including clinical context, intensity of interaction between CHWs and participants, and type of comparator. CHW interventions operate in a variety of clinical contexts; summarizing the effects of these interventions on varied outcomes requires an explicit consideration of the clinical context. For this reason, we have organized the results for KQs 1, 2, and 3 by the clinical context of the interventions identified. These are, specifically, health promotion and disease prevention, injury prevention, maternal and child health, cancer screening, and chronic disease management.

An additional source of heterogeneity is the degree of intensity of the intervention, which can vary by clinical context. We synthesize the evidence from KQ 1 to develop a measure of the intensity (low, moderate, or high) of the interaction between CHWs and participants, and we then include the measure in describing results for KQ 2 and KQ 3. We also record other sources of heterogeneity such as the type of comparator. Chapter 4 discusses the effectiveness of CHW interventions and the potential impact of sources of heterogeneity on effectiveness more fully.

This literature is characterized by several articles together constituting a single study. We refer to studies in the text and cite all relevant articles for each study; article and study counts, therefore, frequently do not match. Our summary tables below feature groups of studies addressing each outcome. Unless otherwise stated, these tables are organized alphabetically by the last name of the first author. The summary tables for KQ 2 and KQ 3 provide information to identify the study (author, and date of publication), study design, population and setting, sample size, study quality, intervention and comparators, and results.

## KQ 1: Interaction of Community Health Workers and Participants

KQ 1 focuses on how CHWs interact with participants, specifically the place of service, type of service, type of educational materials used, duration of interaction with participants, and length of contact. We categorize place of service as over the telephone or based in the clinic, the community, home, or workplace. Interventions often employed multiple settings to interact with participants. The type of services ranged from one-on-one interactions to group interactions. All CHW interventions included some element of education; we sought to understand the degree to which these materials were standardized or tailored for each participant. We identified three elements of duration of interaction: the number of sessions, time per session, and the length of time from the first interaction to the last interaction (length of contact). We report summary findings below, for each descriptor, of the interaction between CHWs and participants across all studies and clinical contexts. These characteristics vary greatly across CHW interventions, but a common element is the overall intensity of the intervention. Interventions of lower intensity will require fewer resources than interventions of moderate or high intensity. As a proxy measure of resource allocation, we employ characteristics of the CHW-participant intervention to develop a measure of intensity of interaction. As noted earlier, a key organizing principle for understanding the effectiveness of CHW interventions is clinical context; we conclude this section by describing characteristics of CHW-participant interactions and their intensity by clinical context. Summary tables describing the characteristics of CHWs are provided by clinical context; within each table, studies are presented in order of intensity and then in alphabetical order, by the last name of the first author.

### Overview of Interaction Between Community Health Workers and Participants

Place of service. CHWs interacted with participants over the telephone or provided services in one or more of four locations: home, community, clinic, or workplace. CHWs provided home, telephone, and clinic interventions on a one-on-one basis; community interventions were more likely to be oriented toward groups than to individuals. Thirty-two studies had at least one home visit but may have involved telephone and community components as well.15,17,18,23,59–102 Interventions in five studies occurred primarily by telephone.19–22,69,70,103–106 In nine studies, interventions included at least one meeting in a community setting and were primarily group-oriented.27,59,60,107–115 Interventions taking place in the community generally occurred in churches59,60,107,108 or in other neighborhood or community locations.27,102,109–114,116–122 Eight studies involved community interventions but did not specify the location;27,109–115,118–120 of these, only two were one-on-one interventions.118–121 One intervention occurred in a neighborhood beauty salon,116 and four occurred on the street or in shelters.117–122 Five studies took place within clinics or health care settings.23,77,99,123–125 One intervention occurred in the workplace.126 We could not determine the place of service for one intervention.16,127

Type of service. The type of services varied greatly across included studies. CHWs provided a wide range of services including one-on-one counseling (face-to-face and by telephone), education, support, information on health and community resources, transportation, appointment reminders, and other forms of assistance. The type of service ranged from brief one-time interactions to intensive one-on-one interactions over a span of years. The minimal service provided was a brief, one-time interaction such as distributing condoms and providing prevention literature117 or a single telephone call to promote cancer screening.103 At the other end of the spectrum, many interventions had multiple face-to-face counseling sessions, often in the home, to address specific needs.

Type of educational materials used. The least described characteristic of the interaction between CHWs and clients is the type of educational material used. As many as twenty-seven studies did not report any details on the type of educational materials utilized.16,19–23,67–74,78,79,83,85–92,96,97,99,101,104–108,117,120–122,124,125,127 Several studies did not describe educational materials per se but did report that they distributed “materials” as part of the intervention (e.g., safety glasses, materials to reduce exposure to asthma triggers, smoke detectors). The remainder provided minimal descriptions that ranged from the use of a postcard66 to complex systems, including audio and written formats to appeal to the broadest range of subjects.63

Duration of interaction (time per session and number of sessions). The duration of interaction varied broadly overall. Interactions lasted from quite brief (5 minutes to an hour) onetime meetings to extensive multiple interactions totaling several hours in all.

Length of contact. The length of contact—that is, the length of time that CHWs were directly involved with participants (which may have differed from the length of the study, or the length of time between measurement of pre- and postintervention health outcomes)—was inadequately reported in many cases. Length of contact ranged from 1 day15,103,108,116,117 to 2.5 years.98

### Intensity of Interaction

Based on the type of interaction, the duration of interaction (time per session, number of sessions, and length of interaction), and the tailoring of CHW interactions, we classified the intensity of an intervention into three categories: low, moderate, or high. Interactions that had at least four of six elements suggesting a higher intensity (one-on-one, face-to-face, an hour per session or more, 3 or more months’ duration, three or more interactions, and tailored materials) were classified as high intensity. Interventions with two or three elements were classified as moderate intensity. Interventions with only one or none of the elements were classified as low intensity.

In making these classifications, we relied, whenever possible, on the protocol intentions rather than what actually occurred. When no information was available for the protocol, we relied on reported interactions in the field. When interactions in the field were also not reported, we assumed lower intensity for that aspect for the intervention. For instance, when studies did not report the time spent in each session, we assumed that the time per session did not exceed an hour on average. Similarly, if studies did not report specifically that the materials were tailored for each participant, we assumed that the interventions used generic materials for all participants.

Low-intensity interventions were generally one-time interactions, usually in a group setting. Moderate-intensity interventions occurred in a variety of settings but typically involved only one or two interactions with CHWs over shorter periods of time. High-intensity interventions included multiple interactions, face-to-face, for 3 months or more. Each category varies internally: for instance, within the high-intensity interventions, the number of interactions could vary from 3 to more than 20 in a year, depending on the nature of the intervention. Of the total of 53 studies, we classified 8 studies as low intensity,19–22,59,60,103,104,107,108,113,117,126 18 as moderate intensity106,125,15,23,63,66,69,70,99,101,102,105,109–112,114,116,118,119,122–124 and 27 as high intensity.16–18,27,61,62,64,65,67,68,71–98,100,120,121,127,128

### Community Health Worker-Participant Interaction by Clinical Context

Community health worker-participant interactions for health promotion and disease prevention intervention. We included 11 studies on health promotion and disease prevention (Table 5). Six studies occurred in the home and by telephone;64–71 one additional study was by telephone and mail.105 Three studies were conducted in community settings—one in a nonclinical site,118,119 one in churches,107 and one on community streets.117 For one study, the place of service was not reported.16,127 The majority of studies did not report the educational materials used; one of these studies provided condoms as part of the intervention.117 Only four studies provided some description of the educational materials used during the intervention.64–66,117–119

Table 5 CHW-participant interactions for health promotion and disease prevention

Author, Date of Publication | Place of Service | Type of Service | Educational and Other Materials Provided | Number of Sessions, Time per Session, and Length of Contact with Participants | Intensity—Low, Moderate, High
Auslander et al., 2002^16^ Williams et al., 2001^127^ | NR | Counseling adults for diabetes prevention: group and individual sessions | NR | 6 group sessions and 6 individual sessions weekly, 45–90 minutes per session, over 3 months | High
Barnes et al., 1999^68^ | Home and telephone | Information and assistance, referral, transportation to clinic if needed for childhood immunizations | NR | Unspecified number of calls and visits, over 6 months (time per session NR) | High
Barnes-Boyd et al., 2001^71^ Nacion et al., 2000^72^ | Home | Family-focused care plan; support, model problem-solving skills, promote self-development of mother, provide instruction in infant care; transportation; find community resources for childhood immunizations | NR | 12 monthly visits, over 1 year (time per visit NR) | High
Conway et al., 2004^67^ | Home and telephone | Problem-solving techniques to reduce environmental tobacco smoke exposure to children | NR | 6 home and telephone visits over 4 months (time per session NR) | High
Elder et al., 2005^64^ Elder et al., 2006^65^ | Home and/or telephone | Home visits or phone calls for Latinas to make healthful dietary behavior changes | Tailored newsletters with homework assignments | 12 home visits or telephone calls over a 12-week period, 12 weekly tailored newsletters (time per session NR) | High
Becker et al., 2005^118^ Cene et al., 2008^119^ | Community-- nonclinical site | Counseling for adults with risk factors for cardiovascular disease | Written, culturally sensitive | Multiple (number unspecified) 30-minute sessions over 1-year period | Moderate
Hunter et al., 2004^66^ | Home | Facilitated appointment scheduling for annual preventive exams for Latinas | Postcard | 1 initial home visit and 1 final followup visit 8 weeks after postcard mailing to begin intervention (time per session NR) | Moderate
Krieger et al., 1999^105^ | Telephone and mail | Referral to medical care; appointment scheduling assistance; appointment reminder letter; followup to determine whether the appointment was kept; a new appointment for each missed appointment (up to 3); and assistance in reducing barriers to care through referral to community transportation, child care, or other services | NR | Various, brief interactions over 3 months (time per session NR) | Moderate
Rask et al., 2001^69^ LeBaron et al., 2004^70^ | Home and telephone | Appointment reminder, assistance in overcoming barriers to appointment for pediatric immunizations if needed | NR | At least 1 telephone call, followed by repeat calls and home visit if no telephone contact, over 15 months or less (time per interaction NR) | Moderate
Campbell et al., 2004^107^ | Community –churches | Provide information through existing networks; organize and conduct at least three church-wide activities focused on spreading information for colorectal cancer prevention | NR | 3 church-based activities during 12 months (time per session NR) | Low
Wendell et al., 2003^117^ | Community —streets | Interview on sexual disease risk factors and prevention in at-risk adults; survey interaction | Condoms | Brief one-time interaction handing out condoms and prevention literature (time of interaction NR) | Low

NR, not reported.

Five studies were of high intensity,16,64,65,67,68,71,127 four of moderate intensity,66,69,70,105,118,119 and two of low intensity.107,117

Community health worker-participant interactions for injury prevention interventions. We included three studies in injury prevention (Table 6).101,102,126 Two took place primarily in the home101,102 and one on farms.126 Two studies involved the distribution of materials to improve safety;102,126 one study did not report the educational materials used.101 Two studies were of moderate intensity;101,102 one was of low intensity.126

Table 6 CHW-participant interactions for injury prevention

Author, Date of Publication | Place of Service | Type of Service | Educational and Other Materials Provided | Number of Sessions, Time per Session, and Length of Contact with Participants | Intensity—Low, Moderate, High
Gielen et al., 2002^101^ | Home | Assessed home for injury hazards such as falls, burns, and poisonings; made recommendations about appropriate safety products and practices; referred families to the Child Safety Center | NR | 1 home-safety visit sometime between the patient’s 6- and 9- month well-infant visits (time of session NR) | Moderate
Schwarz et al., 1993^102^ | Home and community | Recruitment of volunteer representative from each block to identify neighborhood resources, facilitate contacts with residents, and reinforce safety messages through monthly block meetings. Home safety inspections in the presence of residents consisting of provision of safety materials; instruction on correcting safety hazards, simple household repairs, use of ipecac and bathwater thermometer, safety behaviors; identification of community resources | Safety materials: smoke detectors, batteries, bathwater thermometer, nightlight, ipecac, sticker for telephone with emergency numbers, and a poster with information on preventing burns, poisonings, falls, and injury from domestic violence | 1 home visit and monthly block meetings over 18-month period (time per session NR) | Moderate
Forst et al., 2004^126^ | Workplace (farms) | Distribution of eyewear, training on use and on eye health and safety | Reference manual on agricultural eye illness and injury; enlarged photos and fotonovelas; tool kit to demonstrate eye injuries and hazards; protective eyewear | At least 1 individual and at least 1 group session during farming season (time per session NR) | Low

NR, not reported.

Community health worker-participant interactions for maternal and child health interventions. Overall we included 15 studies in maternal and child health (Table 7). All of the studies occurred primarily in the home, but 1 had opportunities for interactions in health care clinics.77 Only 4 studies provided some description of educational materials used during the intervention;75–77,80–82,84 the remaining 11 did not report any details.67,68,71–74,78,79,83,85–87,128 All the maternal and child health studies were of high intensity.

Table 7 CHW-participant interactions for maternal and child well-being

Author, Date of Publication | Place of Service | Type of Service | Educational and Other Materials Provided | Number of Sessions, Time per Session, and Length of Contact with Participants | Intensity—Low, Moderate, High
Barnes-Boyd et al., 2001^71^ | Home | Family-focused care plan; support, model problem-solving skills, promote self-development of mother, provide instruction in infant care; transportation; find community resources | NR | Monthly visits over 12 months (time per session NR) | High
Barnes et al., 1999^68^ | Home and telephone | Information and assistance, referral, transportation to clinic if needed for childhood immunizations | NR | Unspecified number of calls and visits over 6 months (time per session NR) | High
Barth et al., 1988^73^ | Home | Task-directed approach to reduce risk of parenting problems including transportation, support and assistance with participant needs, advocating on participant’s behalf, modeling positive parenting and homecare skills | NR | ≈2 visits per month, ≈ 4 hours per session, over 6 months | High
Barth et al.,1991^74^ | Home | Task-directed approach to reduce the risk of parenting problems | NR | On average 11 visits (range 5–20) over 6 months (time per session not reported but ≈ 4 hours implied) | High
Black et al., 1995^75^ Hutcheson et al., 1997^76^ | Home | Develop individualized family service plan with specific goals; support mother’s needs; promote maternal-child relationship | Handouts, developmental assessment toys | Weekly visits (≈ 1 hour per visit) for 1 year | High
Caulfield et al., 1998^77^ | Community (WIC clinics), home or telephone | One-on-one counseling on participants’ attitudes toward infant feeding, correcting misconceptions, group support sessions on infant feeding | Breastfeeding motivational video, posters and pamphlets | 3 or more meetings during pregnancy (from 24 weeks of gestation) and then weekly up to 16 weeks postpartum if they continued breast feeding (time per meeting NR) | High
Conway et al., 2004^67^ | Home and telephone | Problem-solving techniques to reduce environmental tobacco smoke exposure to children | NR | 6 home and telephone visits over 4 months (time per session NR) | High
Duggan et al., 1999^78^ Duggan et al., 2000^128^ | Home | Building relationships with families; active assistance to address existing crises; model problem-solving skills and effective parent-child interaction; link families with needed resources; provide parenting education; ensuring presence of medical home for children | NR | ≈22 visits (1 hour each) over 2 years | High
Graham et al., 1992^79^ | Home | Psychosocial support; educate family about pregnancy; advocate; link to community services for stress reduction; information on health risks during pregnancy and on nutrition | NR | 4 visits (1 hour each) at 2–4 week intervals for 2–5 months (until birth of child) | High
Nacion et al., 2000^72^ | Home | Intensive home visits for assessment, problem-solving, emotional support, and information | NR | NR | High
Olds et al., 2002^80^ Korfmacher et al., 1999^81^ Olds et al., 2004^82^ | Home | Intensive home visitation: promoting healthy behaviors, competent child care, pregnancy planning, education, employment, linking to social and health services; promoting healthy family/friend relationships | Visit-specific protocol, adapted to individual needs of mother | Every other week (except for weekly visits during the first 4 weeks after enrollment and the first 6 weeks after delivery) through the child’s 21st month, followed by monthly visits during the final 3 months, ≈ 75 minutes per session | High
St. James et al., 1999^83^ | NR (most likely home, based on activities like cooking) | Counseling, meal planning, pregnancy education, shopping, discuss medical recommendations | NR | ≈20 sessions of 2 hours each (weekly in beginning then less frequently) throughout pregnancy | High
Schuler et al., 2000^84^ | Home | Teaching and counseling on infant development, health education, mother-infant interaction | Activity sheets | Weekly visits (mean duration 30.1 minutes per visit) for 6 months | High
Silver et al., 1997^85^ | Home | Counseling; share information on child health and behavior; link families with existing community resources | NR | 6 meetings (1 hour each) with at least biweekly telephone calls and 3 group social activities over 12 months | High
Tessaro et al., 1997^86^ Navaie-Waliser et al., 2000^87^ | Home | Counseling, assistance in applying for government benefits, housing, employment, education, general advocacy for families | NR | One visit per month (more if needed) for approximately 14 months (time per visit NR) | High

≈, approximately; NR, not reported; WIC, Special Supplemental Nutrition Program for Women, Infants, and Children.

Community health worker-participant interaction for cancer screening interventions. Overall 15 studies concerned cancer screening: 7 took place primarily in the home (visits or telephone )15,17–22,61–63,103,104,106 and 8 in community locations59,60,107–113,116,125 (Table 8).

Table 8 CHW-participant interactions for cancer screening

Author, Date of Publication | Place of Service | Type of Service | Educational and Other Materials Provided | Number of Sessions, Time per Session, and Length of Contact with Participants | Intensity—Low, Moderate, High
Paskett et al., 2006^17^ Katz et al., 2007^18^ | Home and telephone | Education and barrier-specific counseling to promote screening; scheduling assistance | Individualized health education program | 2 visits at 45–60 minutes and 30–45 minutes, 2 intervening telephone calls, and a final visit (time of final visit NR) over 9 to 12 months | High
Sung et al., 1997^61^ Sung et al., 1992^62^ | Home | Education on breast and cervical cancer, breast self-exam, educational materials on screening, facilitation to address logistical barriers to screening | Video of Pap and breast exam; printed materials | 3 visits (months 1, 2, 4) over 4-month period, visits 1 and 2 for 1.5 hours each, time for visit 3 NR | High
Dignan et al., 2005^15^ | Home | Barrier-specific counseling to promote screening | Tailored brochure | One-time session of 20–90 minutes | Moderate
Hiatt et al., 1995^125^ | Community (various locations) | One-on-one support; education: contact with clients was ongoing and personal | NR | Unspecified # of interactions (time per interaction NR) over 2 years | Moderate
Jandorf et al., 2005^106^ | Telephone | One-on-one support and education on screening techniques and barriers to screening; assistance scheduling procedures | NR | At least 3 telephone calls (time per call NR) over 6 months | Moderate
Mock et al., 2007^109^ | Community | 2 small group gatherings and individual direct contacts to help access medical services and schedule appointments | Language-specific flip charts and booklets | 2 sessions of 90 or 120 minutes each over 3 to 4 months | Moderate
Navarro et al., 1995, 1998, 2000^110–112^ | Community | 12 weekly small group educational sessions | Pamphlets, worksheets, posters developed for project and pamphlets from other organizations | 12 sessions of 90 minutes each over 3 months | Moderate
Taylor, et al., 2002^63^ | Home and telephone | Tailored responses to individual barriers to cervical cancer screening, clinic referral and scheduling assistance, translation services, transportation assistance | Video, motivational pamphlet, educational brochure, fact sheet, tailored counseling | One-time visit with followup telephone call (time per interaction NR) | Moderate
Wilson et al., 2008^116^ | Community—beauty salon | Education, counseling, and information on location of screening services during salon appointment | Written materials (not described) | 1 visit (time of session NR) | Moderate
Andersen et al., 2000^103^ | Telephone | Barrier-specific telephone counseling to promote screening | Standardized script | 1 interaction (time of interaction NR) | Low
Campbell et al., 2004^107^ | Community—churches | Provide information through existing networks; organize and conduct at least 3 church-wide activities focused on spreading information | NR | 3 church-based activities during 12 months (time per session NR) | Low
Derose et al., 2000^19^ Duan et al., 2000^20^ Derose et al., 2000^21^ Fox et al., 1998^104^ Stockdale et al., 2000^22^ | Telephone | Barrier-specific telephone counseling to promote screening, discussion of resources for free- and reduced-cost mammograms, translation services, transportation, and childcare assistance | NR | 2 telephone calls (1 per year over 2 years), time per session 7–11 minutes on average | Low
Earp et al., 2002^113^ | Community | Presentations to community groups and events; one-on-one conversations; use of informational/motivational materials | Brochures, posters, church fans, holiday cards | 2 community activities per month; one-on-one conversations once a week over a 24-month period, time per session NR | Low
Erwin et al., 1997^108^ | Church | Motivational speeches based on cancer survivor experience of CHWs, breast self-exam lessons using a breast model, discussion of resources for free- and reduced-cost mammograms | NR | 1 presentation, time NR | Low
Sauaia et al., 2007^59^ Welsh et al., 2005^60^ | Community (church) and home | Personal education sessions to deliver health promotion messages | Newsletter | At least bimonthly meetings (time per meeting NR) over 5 years | Low

NR, not reported.

Nine studies described some of the materials used during the intervention;15,17,18,59–63,103,109–113 six did not report the educational materials used.19–22,104,106–108,116,125 We found two studies of high intensity,17,18,61,62 seven of moderate intensity.15,63,106,109–112,116,125 and six studies of low intensity.19–22,59,60,103,104,107,108,113

Community health worker–participant interactions for chronic disease management interventions. Overall, 13 studies focused on chronic disease management (Table 9). Seven took place primarily in the home,23,88–100 2 in health care settings123,124 and 4 in community locations.27,114,120–122 Eight described some of the materials used during the intervention;27,93–98,100,114,123 five did not report the educational materials used.23,88–92,99,120–122,124 Two studies provided materials to households to reduce exposure to asthma triggers (bedding, vacuum cleaners, etc.). 96,97,100 Eight were of high intensity 27,88–98,100,120,121 and five studies were of moderate intensity.23,99,114,122–124

Table 9 CHW-participant interactions for chronic disease management

Author, Date of Publication | Place of Service | Type of Service | Educational and Other Materials Provided | Number of Sessions, Time per Session, and Length of Contact with Participants | Intensity—Low, Moderate, High
Batts et al., 2001^88^ Gary et al., 2003^89^ Gary et al., 2005^90^ Gary et al., 2000^91^ Vetter et al., 2004^92^ | Home and telephone | Offer to schedule appointments and visits, provide education, mobilize social support for adults with diabetes mellitus | NR | 3 visits (45–60 minutes each) per year over 2 years (and additional contacts as needed) | High
Beckham et al., 2008^93^ | Home or clinic (site chosen by participant; majority preferred home) | Diabetes self-management education; referrals to registered dieticians, healing center | Visual aids (majority of participants illiterate) | Up to 15 home visits over 1 year, lasting 1–1.5 hours per visit | High
Frate et al., 1985^94^ Frate et al.,1983^95^ | Home or community | Monitor blood pressure; provide health education and support; self-management of hypertension for adults | Pamphlets, scale, low-salt cookbook, AHA and NHLBI pamphlets | Monthly visits over 18 months (time per session NR) | High
Krieger et al., 2005^96^ Krieger et al., 2002^97^ | Home | Environmental assessment; individualized action plan; education and social support; deliver materials to reduce trigger exposure for asthma | Materials to reduce asthma-trigger exposure | 4 to 9 visits over 12 months (time per session NR) | High
Levine et al., 2003^98^ | Home | Education, counseling, referrals, providing information on access to health care, answered questions for adults with hypertension | Wallet-sized blood pressure tracking card, educational pamphlet | 6 visits over 2.5 years (time per visit NR) | High
Lujan et al., 2007^27^ | Community (classroom), telephone, and mail | Deliver participative classes for adults with diabetes mellitus, answered questions, reinforce education, promote behavior change, send biweekly postcards | Audiovisual teaching aids (flip charts, food models, food labels) and handouts | 8 weekly 2-hour classes + biweekly telephone calls for 8 weeks followed by biweekly postcards for 16 weeks 24 weeks’ total duration of interaction with participants | High
Morse et al., 1997^120^ Wolfe et al., 1997^121^ | Community—unspecified locations (homeless population) | Assistance with activities of daily living and leisure activities for homeless people with psychiatric diseases | NR | Face-to-face meetings (time per meeting and number NR) over 18 months | High
Parker et al., 2008^100^ | Home | Environmental assessment; asthma action plan based on allergy tests; education and social support; mattress covers, pillows, vacuum, cleaning supplies; counseling on environmental tobacco smoke; integrated pest management services | Asthma booklet; materials to reduce asthma trigger exposure | At least 9 visits over 12 months (time per session NR) | High
Bone et al., 1989^123^ | Emergency room and telephone | Measured pulse and blood pressure (in emergency room session); provided educational counseling; identified barriers related to referrals, appointment keeping, and adherence to the treatment plan for adults with hypertension | Wallet-sized BP record card | 1 face-to-face session (≈20 minutes) and at least 1 pre-followup appointment reminder telephone call (5–10 minutes) (time period over which this occurred NR) | Moderate
Corkery et al., 1997^124^ | Hospital clinic | Liaison between patients and health care providers for adults with diabetes mellitus; attended clinic sessions with patient; provided translation, appointment reminders; rescheduled missed appointments; reinforced self-care instructions | NR | Varied (mean = 3.4 months, range: 0.9–5.4), time per session equal to clinic visit duration | Moderate
Morisky et al., 2002^23^ Ward et al., 2000^99^ | Home and/or clinic | Counseling regarding lifestyle, medication-taking, and appointment-keeping; tailored to patient need for adults with hypertension | NR | Number of visits, time per session, time period over which interactions occurred NR | Moderate
Pilote et al., 1996^122^ | Community—shelters (homeless population) | Transported participants to clinic appointment for homeless people with tuberculosis; assisted with paperwork and doctor’s recommendations | None | Met participants and went to clinic within a 3 week period (time per session NR) | Moderate
Von Korff et al., 1998^114^ | Community—unspecified locations | Led classes on self-managing back pain, discussed strategies and barriers to achieve goals for managing pain | Book, pamphlets, videotapes, flipcharts | 4, 2-hour classes held once a week for 1 month | Moderate

NR, not reported.

## KQ 2: Outcomes of Community Health Worker Interventions

KQ 2 asks about the impact of CHWs on outcomes, particularly knowledge, behavior, satisfaction, health outcomes, and health care utilization. As noted earlier, the effect of CHW interventions will vary by clinical context (e.g., diagnosis or health concern), so as with KQ 1, we present results by clinical context for each of the outcomes described above. The areas of clinical concern are health promotion and disease prevention, injury prevention, maternal and child health, cancer screening, and chronic disease management.

We also assessed each study for quality; in general, we present results for higher quality studies first, followed by findings for moderate and then lower quality studies. We also give the level of intensity of the interaction between CHWs and participants and the type of comparator for each study, using the three intensity categories introduced in KQ 1. As noted there, the intensity of the interaction between CHWs and participants varied by clinical context. For example, maternal and child health interventions were solely high intensity whereas cancer screening studies ranged across high, medium, and low intensity. Because of this variation for cancer screening, we discuss those studies categorized first by intensity, then by quality. For all other clinical contexts, we did not find meaningful patterns by intensity of intervention, either because of lack of variation in intensity, or because the number of studies was insufficient to draw conclusions.

Variation in aims and clinical contexts of the studies, populations and settings, measures of health outcomes, and health care utilization information precluded quantitative synthesis of the results of studies. As with other questions, the number of articles exceeds the number of distinct studies. In all cases, tables list studies by quality (good, fair, then poor) and then alphabetically by last name of the first author of the article(s).

### Outcomes for Health Promotion and Disease Prevention

Health promotion and disease prevention: pediatric immunizations. Study characteristics. Two RCTs, one good69,70 and one fair quality,68 and one poor-quality prospective cohort study (REACH-Futures71,72) examined outcomes of CHW interventions to improve pediatric immunization rates in inner cities (Table 10). The RCTs used moderate-intensity interventions and the cohort study used a high-intensity intervention.

Table 10 CHWs and health promotion and disease prevention: pediatric immunization interventions

Author, Year Study Design Population Setting Sample Size Quality | Intensity of CHW Intervention | Study Groups | Results
Rask et al.,, 2001;^69^ LeBaron et al., 2004^70^ RCT Pediatric Immunizations Children <12 months in a county public health clinic in metropolitan Atlanta, Georgia N: 3,050 Good | Moderate | G1: Autodial – automated telephone call delivered recorded message from health department medical staff; if no number or nonworking – then postcard to remind families 7 calendar days before child was due to be immunized G2: Outreach – Following standardized protocol, outreach worker contacted patient within 1 week and made reminder call before appointment; if child still not up to date, monthly home visits attempted G3: Combination of G1 and G2 G4: Normal clinic procedure (control) | Vaccine series completed per immunization registry after 22 months: No statistical difference between CHW and control groups
Barnes et al., 1999^68^ RCT Pediatric Immunizations Low-income children in Manhattan, New York N: 434 Fair | Moderate | G1: Basic immunization education and referral. During subsequent contacts (home visits or telephone calls) throughout the remainder of followup, families were reminded of upcoming vaccinations and were recontacted to ensure that requisite vaccines were received. Contact with the clinic or escort to appointments provided if a family required support or assistance to obtain immunization services. G2: Informed of their child’s immunization status at the enrollment visit by the control group interviewer and were instructed to reschedule the missed appointment. | Up-to-date on immunizations after 6 months: G1: 75% G2: 54% (P = 0.03) Late for immunization: G1: 18% G2: 38% (P < 0.05)
Barnes-Boyd et al., 2001^71^ Prospective Cohort Pediatric Immunizations Low-income inner-city African-American women and infants in Chicago, Illinois N: 1,922 Poor | High | G1: Monthly home visits over 1 year; visits at prenatal, 1, 6, and 12 months teamed with a nurse. G2: Historic controls with nurse home visits. | Percent fully immunized at 12 months: G1: 77% G2: 63% (P <0.001)

CHW, community health worker; G, group; N, number; RCT, randomized controlled trial.

Both RCTs used CHWs to provide reminder telephone calls for upcoming clinic appointments. The good-quality RCT, targeting children < 12 months of age in a county public health clinic in metropolitan Atlanta, had CHWs make home visits only if a child remained behind on his or her immunization schedule.69,70 Additionally, this study compared four groups of children receiving: (1) automated telephone call reminders, (2) CHW outreach, (3) a combination of a CHW and automated telephone call reminders, and (4) a control group defined by normal clinic procedure.69,70 Outcomes were assessed after 22 months.69,70

The fair-quality trial, targeting low-income children in Manhattan, also used CHWs to provide basic immunization education and referral, in addition to assisting in obtaining immunization services through a combination of telephone and home visits.68 It compared outcomes after 6 months for children receiving the CHW intervention with those for a control group comprising parents who were informed of their child’s immunization status at enrollment and instructed to reschedule the missed appointment.68

REACH-Futures, a prospective cohort study, compared a group receiving a high-intensity intervention of CHW and nurse visits with historic controls of nurse-only home visits.71,72 Monthly home visits started prenatally and ended at 1 year.71,72 We rated this study poor because of high potential for secular trends, given the time difference between the two groups, and for other confounding problems.71,72

Overview of results. These three studies68–72 evaluated the impact of CHWs on vaccine series completion rates and showed different CHW effectiveness. The good-quality study found no difference between groups receiving the CHW intervention and the control group.69,70 In contrast, the fair-quality study demonstrated that children in the CHW group were more up-to-date and less likely to be late for their immunizations than the controls.68 The control group for this study received more intervention directed at improving immunization rates, which would diminish the apparent effectiveness of the CHW. This study was more intensive than either of the other two projects (regular home visits or telephone calls over 6 months to ensure that requisite vaccines were received); this factor may have produced the difference in effectiveness between studies. REACH-Futures71,72 also found that the CHW-intervention group had a higher proportion of fully immunized participants at 12 months than did the historic controls who had received a nurse-only home visit.

Knowledge. No study reported outcomes for improved knowledge of pediatric immunization.

Behavior. No study reported outcomes for behavior changes.

Satisfaction. No study reported outcomes for satisfaction.

Health outcomes. All three studies evaluated immunization rates. The good-quality trial evaluated vaccine series completion rate from an immunization registry and found no difference between the CHW and control groups.69,70 The fair-quality trial found that children in the CHW arm were more up-to-date on immunizations than in the control arm (75 percent versus 54 percent, P = 0.03) and that fewer children were late for immunizations (18 percent versus 38 percent, P < 0.5).68 The poor-quality study evaluated vaccine series completion rates at 12 months and found that a higher proportion of children receiving the CHW and nurse home visits were up-to-date than historical controls (P < 0.001).71,72

Health care utilization. No study reported outcomes for health care utilization.

Health promotion and disease prevention: health promotion – Latina health. Study characteristics. Two RCTs, one fair66 and one poor quality,64,65 examined outcomes of CHW interventions in comparison with mailings for health promotion in Latinas (Table 11). The fair-quality study used a moderate-intensity CHW intervention in uninsured Hispanic women age 40 years and older living at the US-Mexico border (Agua Prieta, Sonora, Mexico, and Douglas, Arizona, United States) with the aim of increasing return to clinic for an annual preventive examination.66 It compared a group receiving CHW home visits in addition to reminder postcards with a group getting reminder postcards alone.

Table 11 CHWs and health promotion and disease prevention: Latina health promotion interventions

Author, Year Study Design Population Setting Sample Size Quality | Intensity of CHW Intervention | Study Groups | Results
Hunter et al., 2004^66^ RCT Annual preventive exams Uninsured Hispanic women, aged 40 and older, living at the US-Mexico border N: 103 Fair | Moderate | G1: Received postcards in the mail 2 weeks before the month their annual exams were due, printed in language used to complete original questionnaire G2: Received G1 intervention and were visited by a promotora 2 weeks after the postcard had been mailed. Promotora facilitated appointment scheduling and contacted them to facilitate rescheduling if appointment was missed. | Return to clinic for a second comprehensive annual exam: G1: 48% (n = 24) G2: 65% (n = 33) RR, 1.35; 95% CI, 0.95–1.92
Elder et al., 2006;^65^ Elder et al., 2005^64^ RCT: Secretos de La Buena Vida Dietary behavior, changes Latinas in San Diego County, California N: 357 Poor | High | G1: CHW home visits and/or telephone calls + tailored print materials G2: 12 weekly tailored newsletters and homework G3: 12 weekly off-the-shelf dietary printed material | Total fat gm, total fiber gm (Nutrition Data System 24-hour dietary recall interview) (validated): No significant difference between groups at 6 and 12 months postintervention

CHW, community health worker; CI, confidence interval; G, group; N, number; RCT, randomized controlled trial; RR, risk ratio.

The poor-quality study, Secretos de la Buena Vida, used a high-intensity CHW model in the same target population living in San Diego County, California.64,65 It evaluated the effectiveness of weekly CHW home visits and telephone calls in addition to tailored print materials against that of tailored materials alone or off-the-shelf materials for changing dietary behavior. We rated this a poor-quality study because of a high potential for selection bias, measurement bias, and confounding.64,65

Overview of results. The fair study found that a moderate-intensity CHW intervention was more effective than a reminder postcard in increasing preventive exam appointments.66 The poor-quality study demonstrated that a high-intensity CHW intervention group was different from those receiving weekly tailored dietary printed material in terms of dietary intake immediately post-intervention. This difference was no longer apparent after 6 months, although all three groups improved.64,65

Knowledge. Neither study reported outcomes for improved knowledge of health promotion.

Behavior. The Secretos de la Buena Vida project examined behavioral changes.64,65 The CHW arm and the tailored print arm did not differ significantly at 6 and 12 months postintervention in dietary intake of fat or fiber, based on a validated measure for 24-hour diet recall.

Satisfaction. Neither study reported outcomes for satisfaction.

Health outcomes. Neither study reported outcomes for improved health.

Health care utilization. The fair-quality, moderate-intensity CHW study reported on the percentage of women returning to clinic for a second annual preventive examination.66 The CHW arm had a higher percentage of women returning than the postcard-only arm (65 percent versus 48 percent; RR, 1.35; 95percent CI, 0.95–1.92), but the difference was not statistically significant.

Health promotion and disease prevention: disease prevention. Study characteristics. Six studies, five RCTs16,67,105,107,118,119,127 and one prospective cohort study,117 examined outcomes of CHW interventions for disease prevention in underserved populations throughout the United States (Table 12). Two studies were both high intensity and fair quality;16,67,127 two studies were moderate intensity, one fair105 and one poor quality;118,119 and two studies were low intensity, one fair117 and one poor quality.107 Studies focused on a broad range of disorders, including cardiovascular disease prevention,105,118,119 diabetes prevention,16,127 HIV prevention,117 colorectal cancer prevention,107 and second-hand smoke exposure.67 Of the five RCTs, three were of fair quality16,67,105,127 and two were poor.107,118,119

Table 12 CHWs and health promotion and disease prevention: disease prevention interventions

Author, Year Study Design Population Setting Sample Size Quality | Intensity of CHW Intervention | Study Groups | Results
Auslander et al., 2002;^16^ Williams et al., 2001^127^ RCT Diabetes prevention Low-income African-American women in a large city (unspecified) in Missouri N: 294 Fair | High | G1: 6 group sessions (approximately 6 to 8 participants per group) and 6 individual sessions targeting stages of change to tailor, dietary pattern with a peer educator, meeting weekly over a 3-month period G2: A book (control) | Food Frequency Questionnaire – Validated: Intervention was effective in reducing fat intake, as measured by percentage of calories from total fat (baseline/6 months): G2: 36.0/34.5 G1: 35.9/32.3 (P < 0.05) BMI: No significant difference between groups Knowledge of Label Reading Questionnaire (unvalidated) baseline/6 months: G2: 5.4/5.7 G1: 5.5/6.3 (P > 0.0001)
Conway, 2004^67^ RCT Secondary tobacco smoke Latino neighborhoods in San Diego County, California N: 143 Fair | High | G1: Culturally relevant home and telephone visits on problem-solving techniques to reduce ETS exposure G2: No intervention (control) | RIA of child's hair for nicotine and cotinine (validated): No significant difference between groups
Krieger, 1999^105^ RCT Hypertension Low-income neighborhoods in Seattle, Washington N: 421 Fair | Moderate | G1: CHW assistance with medical followup related to a date when blood pressure was determined to be elevated G2: Advice to see medical provider, list of public and community clinics | Self-report of completed followup appointment within 90 days (validated by medical provider report): G1: 65.1% G2: 46.7% (P = 0.001)
Wendell, 2003^117^ Prospective cohort study HIV prevention At-risk neighborhoods in Louisiana N: 6,547 Fair | Low | G1: Discussions with community members during which they assessed the client’s needs, imparted a risk- or harm-reduction message, answered questions, made referrals, and negotiated and reinforced behavior change G2: No intervention (control) | Condom use (intervention vs. comparison): OR, 1.37 (95% CI, 1.20 to 1.56; P < 0.001)
Becker et al., 2005;^118^ Cene et al., 2008^119^ RCT Cardiovascular disease prevention Baltimore, Maryland N: 267 Poor | Moderate | G1: EPC- received risk-specific materials (same as intervention group), PCP received results and recommendations, sent info on local programs (e.g., YMCA) G2: CBC - received care in 1 nonclinical site in the community from a NP and CHW. CHW provided dietary counseling, smoking cessation, and exercise counseling lasting 30 minutes. | Smoking cessation (self-report): G1: 7% reduction G2: 16.2% reduction (P < 0.001)
Campbell, 2004^107^ RCT Colorectal cancer screening African-American rural churches in North Carolina NR (12 churches; completers/dropouts of individual participants from each church not reported) Poor | Low | G1: Control churches were offered health education sessions and speakers on topics of their choice not directly related to study objectives G2: Organize and conduct at least 3 church-wide activities on spreading info and enhancing support for healthy lifestyle and CRC screening (LHA) G3: 4 personalized computer- tailored newsletters and 4 targeted videotapes corresponding to the same behaviors mailed to participants' homes bimonthly for first 6 months after baseline data collection; 4th mailing was 9 months baseline G4: LHA + targeted print and videotape | Dietary change—daily fruit and vegetable servings (baseline/followup): G1: 3.3/3.4 G2: 3.5/3.5 G3: 3.3/3.9 G4: 3.4/3.7 No significant change across arms for LHA interventions Physical activity—recreational (moderate-vigorous) activity MET hours/week, M (SE) (baseline/followup): G1: 9.3(0.88)/8.4(0.69) G2: 10.5(0.9)/10.6(0.70) G3: 9.5(0.80)/10.9(0.61) G4: 9.7(0.76)/9.7(0.60) No significant change across arms for LHA interventions

BMI, body mass index; CBC, community-based care; CHW, community health worker; CI, confidence interval; EPC, enhanced primary care; ETS, environmental tobacco smoke; LHA, lay health advisor; MET, metabolic equivalent; N, number; NP, nurse practitioner; OR, odds ratio; PCP, primary care physician; RCT, randomized controlled trial; RIA, radioimmunoassay; SE, standard error; YMCA, Young Men’s Christian Association.

The Missouri study was a fair-quality RCT evaluating a high-intensity CHW intervention focused on diabetes prevention in a low-income, African-American female population.16,127 This study compared 3 months of weekly sessions, alternating between group and individual sessions, targeting stages of change to tailor dietary patterns, with a control group that received a book to read.16,127 The San Diego study was a fair-quality RCT evaluating a high-intensity CHW intervention focused on decreasing secondary tobacco smoke exposure in Latino neighborhoods in San Diego County, California.67 The intervention consisted of six home and/or telephone visits by CHWs over 4 months using culturally tailored behavioral problem-solving techniques to reduce secondary tobacco smoke exposure; controls received no intervention.67 The Seattle, Washington, study was a fair-quality RCT evaluating moderate-intensity CHW assistance with medical followup against verbal advice to see a medical provider in low-income neighborhood participants who were found to have elevated blood pressure.105

The sole prospective cohort study, rated fair quality, evaluated the effectiveness of a low-intensity CHW intervention in HIV prevention by street outreach to at-risk community members in Louisiana compared with a control group in a neighborhood receiving no intervention.117

The poor-quality Baltimore, Maryland, trial evaluated a moderate-intensity intervention consisting of a nurse practitioner and CHW team at a nonclinical site with exercise equipment; CHWs provided dietary, smoking cessation, and exercise counseling.118,119 This strategy was compared with “enhanced” primary care, in which the same risk-specific materials and information on local programs were given to the intervention group and results and recommendations were provided to the patients’ primary care physicians. We rated it poor because of a high potential for measurement bias.118,119 The WATCH trial was a poor-quality RCT of low intensity conducted in rural, predominantly African-American churches in North Carolina.107 This study had four arms: (1) control churches offered a health education session and speakers not related to study objectives; (2) CHW intervention, consisting of organization and presentation of at least three church-wide activities on educating and enhancing support for healthy lifestyle and colorectal cancer screening; (3) four personalized computer-tailored newsletters and four targeted videotapes focused on healthy lifestyle and colorectal screening mailed bimonthly to participants’ homes; and (4) both the CHW and the videotape components.107

Overview of results. These six disease prevention studies reported on outcomes of knowledge, behavior, health outcomes, and health care utilization. Overall, four studies found that a CHW intervention was more effective in achieving outcomes than the respective control group.16,105,117–119,127 Two fair-quality studies (the Missouri trial16,127 and the prospective cohort study117) reported improved knowledge of the respective diseases in the CHW intervention as compared to respective controls. Two fair-quality studies (the Missouri trial16,127 and the prospective cohort study117) and one poor-quality study (the Baltimore trial118,119) demonstrated that moderate- and low-intensity CHW interventions were more effective than controls in changing health behaviors.

The two studies that targeted tobacco cessation found opposing results regarding CHW effectiveness.67,118,119 The fair-quality study (San Diego trial67) found no difference in smoking cessation between a high-intensity CHW intervention group and a group receiving nothing based on validated radioimmunoassay (RIA) of children’s hair for nicotine and cotinine. The poor-quality study (Baltimore trial118,119) found a significant difference between a moderate-intensity CHW intervention and enhanced usual care; however, this outcome was based on self-report. The fair-quality Seattle trial measured health care utilization and demonstrated that a moderate-intensity CHW intervention increased medical followup compared with only verbal advice to seek medical care for elevated blood pressure.105

Overall, most (four of the six) disease prevention studies demonstrated that various levels of CHW intervention intensity (low, moderate, or high) were more effective than the comparator, which ranged from nothing to enhanced usual clinical care, in changing a variety of outcomes.

Knowledge. Two fair-quality studies16,117,127 reported outcomes for improved knowledge of the respective diseases. The Missouri study16,127 found that participants in the high-intensity, diabetes-oriented CHW intervention, compared with a control group receiving a book to read, had an improved knowledge of label reading as assessed by an unvalidated questionnaire (P < 0.0001); this improvement remained statistically significant at 6-month followup. The prospective cohort study117 demonstrated that a low-intensity CHW street outreach program was effective at increasing knowledge of where to obtain free condoms as determined by an unvalidated questionnaire (90 percent versus 74 percent, odds ratio [OR], 3.2, P = 0.001).

Behavior. Five RCTs, three fair16,67,105,127 and two poor quality,107,118,119 examined a variety of behavioral changes. Three demonstrated CHW effectiveness16,105,118,119,127 and two67,107 showed no difference compared with their respective controls. The Missouri trial on diabetes prevention evaluated dietary change following high-intensity, CHW-led group and individual sessions;16,127 it found a reduction in fat intake with a validated food frequency questionnaire compared with intake in a control group (P < 0.0001). The San Diego trial, a high-intensity CHW intervention of home and telephone visits to reduce second-hand tobacco smoke exposure to children, found no difference from baseline by self-report or validated RIA of children’s hair for nicotine and cotinine.67 In contrast, the Baltimore trial evaluated a CHW intervention and found a difference in self-reported smoking cessation as compared to a standard of care group (16.2 percent reduction versus 7.0 percent, P < 0.001).118,119 Both groups reported less smoking, confirmed by measures of hair cotinine. The North Carolina trial did not show a difference in either fruit and vegetable intake or increased physical activity between intervention and control groups.107 The prospective cohort low-intensity study targeting HIV prevention demonstrated an increase in condom use reported in the intervention group (OR, 1.37; 95 percent CI, 1.20–1.56).117

Satisfaction. No study for health promotion evaluated outcomes focused on satisfaction.

Health outcomes. The Missouri trial found no difference within or between arms when comparing the high-intensity CHW intervention and the control group in terms of body weight and body mass index (BMI) at baseline (BMI 35.7 versus 35.3) and after 6 months (BMI 35.7 versus 35.4).16,127

Health care utilization. The Seattle trial evaluated self-reported medical provider followup within 90 days of determined elevated blood pressure.105 It demonstrated a higher rate of completed medical followup in the CHW group than in the control group (65.1 percent versus 46.7 percent, P = 0.001). The number needed to treat in order to bring 1 person to medical care was 5 (95 CI, 3–13).105

### Outcomes for Injury Prevention

Injury prevention: home safety. Study characteristics. One fair-quality RCT101 and one poor-quality RCT randomized at the community level (called the Safe Block Project)102 assessed the effect of low-intensity CHW interventions on injury prevention in homes, either for children101 or for all ages.102 Both studies involved CHW home visits. The fair-quality RCT consisted of assessment of safety hazards and recommendations for appropriate products and practices compared with safety counseling in a pediatric clinic.101 The poor-quality RCT also included direct implementation of several safety features into homes compared with no intervention in control households; we rated this trial poor because of its high potential for measurement bias and not masking those who assessed outcomes.102

Overview of results. The fair-quality RCT showed no benefit to CHW intervention,101 but the poor-quality trial had mixed results102 (Table 13.). Significant benefit was seen for household features that did not require participants to change behaviors (e.g., continued presence of a smoke detector, as installed in intervention homes); conversely, no benefit was observed for other household features that did require behavior change (e.g., maintaining a working light bulb in stairways).

Table 13 CHW injury prevention interventions and home safety

Author, Year Study Design Population Setting Sample Size Quality | Intensity of CHW Intervention | Study Groups | Results
Gielen et al., 2002^101^ Parents and infants 6 months or younger in large urban teaching hospital pediatric clinic Baltimore, Maryland N: 187 Fair | Moderate | G1: Safety counseling and referral by pediatrician to children’s safety center G2: Standard care plus offer of CHW home visit; assessed injury hazards; made recommendations about appropriate safety products and practices; referred families to the children’s safety center; 1 visit between 6 and 9 months | No significant difference between groups in home safety practices: Hot water temperature controlled: Pre/Post G1: 39%/47%; G2: 39%/47% Working smoke alarm: Pre/Post G1: 92%/84%; G2: 92%/81% Safety gates used: Pre (planned use)/Post (actual use) G1: 84%/23%; G2: 84%/27% Poisons latched/locked: Pre/Post G1: 26%/12%; G2: 26%/10% Ipecac present: Pre/Post G1: 12%/27%; G2: 12%/31%
Schwarz et al., 1993^102^ (Safe Block Study) Inner city residents in neighborhoods with high injury rates Philadelphia, Pennsylvania N: 2,722 Poor | Moderate | G1: Safety inspections, home modifications and education; myriad safety devices (e.g., smoke detectors, ipecac, emergency telephone numbers, light bulbs) G2: Control (details NR) | G1 more likely than G2 to retain intervention modifications such as presence of ipecac (P < 0.001), hot water temperature control (P < 0.001) No difference between groups for adequate lighting at stairs

CHW, community health worker; G, group; N, number.

Knowledge. Neither study assessed knowledge-related outcomes.

Behavior. In the fair-quality RCT,101 groups did not differ significantly in maintaining adequate stairway lighting (83.1 percent versus 80.1 percent; adjusted odds ratio [AOR], 0.90; 95 percent CI, 0.69–1.16) or in following any of the home safety practices assessed. Hot water temperature control and presence of ipecac increased from baseline in both groups, but presence of a working smoke alarm, use of safety gates on stairs, and latching or locking of poisons declined from baseline. In the poor-quality trial,102 following the CHW intervention a significantly higher proportion of households continued to have ipecac (which was recommended at the time of the study for households with young children) (81.0 percent versus 9.8 percent; AOR, 0.04; 95 percent CI, 0.02 to 0.07) and smoke detectors (96.0 percent versus 77 percent; AOR, 0.14; 95 percent CI, 0.09 to 0.20) than did controls. These interventions were provided by the CHWs and required no behavior change by participants. In contrast, intervention households were actually less likely than control households to have retained hot water temperature controls (63.2 percent versus 73.2 percent; AOR, 1.73; 95 percent CI, 1.39 to 2.15).

Satisfaction. Neither study assessed satisfaction.

Health outcomes. Neither study assessed direct health outcomes.

Health care utilization. Neither study assessed health care utilization.

Injury prevention: workplace safety. Study characteristics . One prospective cohort study, rated poor quality for high potential for selection and measurement bias and lack of description of baseline characteristics, examined the effect of a low-intensity CHW intervention for migrant farm workers to prevent work-related eye injury. The CHW intervention involved distribution of protective eyewear either with or without specific training provided by the CHWs; it was compared to distribution of eye protection not involving CHWs. Outcomes were assessed during the same growing season in parts of the Midwest.

Overview of results. The CHW intervention increased the likelihood of protective eyewear use, particularly when coupled with CHW-led training (Table 14).126

Table 14 CHW injury prevention interventions and workplace safety

Author, Year Study Design Population Setting Sample Size Quality | Intensity of CHW Intervention | Study Groups | Results
Forst et al., 2004^126^ Latino migrant and seasonal farm workers Southeast Michigan and northeast Illinois N: 786 Poor | Low intensity | G1: CHW distributed protective eyewear, conducted at least 1 each individual and group training sessions G2: CHW distributed eyewear, did not provide training G3: No CHW component | G1 were more likely to increase use of protective eyewear compared with G2 (P < 0.0001) and with G3 (P = 0.03) Any CHW intervention increased likelihood of protective eyewear use vs. no CHW (P = 0.0004)

CHW, community health worker; G, group; N, number.

Knowledge. Knowledge was not assessed.

Behavior. The presence of any CHW component related to receiving protective eyewear was significantly associated with increased self-report of continued use of the eyewear on a 5-point Likert scale compared with having received the eyewear without CHW involvement (difference in average change in Likert scale value 0.6452, P < 0.01). Incorporation of CHW-led training was associated with greater self-reported eyewear use compared with CHW eyewear distribution alone (difference in average change 0.7663, P < 0.01) and with no CHW involvement (difference in average change 0.5241, P = 0.03). Observed use of eyewear increased in all groups during the study period (CHW trained 1.1 to 36 percent; CHW distributed 0 to 5.2 percent; no CHW 0 to 14 percent, P-value not reported).

Satisfaction. Satisfaction was not assessed.

Health outcomes. Although the investigators measured the incidence of pterygium, they did not compare groups on this variable and in fact reported it as only inadequately identified.

Health care utilization. No measure of health care utilization was reported.

### Outcomes for Maternal and Child Health

Maternal and child health: overview. We identified 15 studies that met inclusion criteria and involved maternal or child health outcomes (or both). All the studies utilized high-intensity interventions, usually involving some series of home visits. All but 1 study were rated either fair (8 studies) or poor (6 studies). The 1 good-quality study found no significant differences associated with interventions employing CHWs. Among the other studies, results were mixed, some showing benefit of CHW interventions and some showing no effect attributable to CHWs. This distribution was found in both fair- and poor-quality studies. Significant associations were most commonly found for existing conditions (e.g., phenylketonuria [PKU] or failure to thrive) rather than primary prevention and in the area of health care utilization (e.g., immunization rates) and behavior (e.g., parenting measures).

Maternal and child health: prenatal care and perinatal outcomes. Study characteristics. Six studies assessed prenatal care and perinatal outcomes associated with CHWs.71,72,77,79,83,86,87 Of these, three were rated fair quality: one RCT involving prenatal care in Cleveland79 and two cohort studies (one on the Resource Mothers Program for Maternal PKU83 and one evaluating REACH-Futures72). The remaining three studies, rated poor, included one RCT on promotion of breastfeeding in African-American mothers in Baltimore,77 rated poor for high attrition and lack of specific or validated outcome measures; one cohort study (the Baby Love Maternal Outreach Worker study31,32), rated poor for high attrition, high potential for selection bias and confounding, and lack of specific or validated outcome measures; and a second study on REACH-Futures71 rated poor for high potential for secular trend and other confounding.

Most studies focused on interventions for low-income families, usually from racial or ethnic minority groups. Most CHW interventions involved home visits. The Resource Mothers Program for Maternal PKU83 involved coaching in activities of daily living unique to mothers with PKU infants including meal planning and medical recommendations concerning pregnancy. The Maternal Outreach Worker program also provided direct assistance to families for obtaining benefits and services.86,87

Studies generally compared outcomes for families receiving CHW interventions with outcomes for those receiving usual clinical care (Table 15). The Baltimore breastfeeding study compared CHW intervention with video and other literature and against both interventions combined;77 the Resource Mothers Program83 used as controls mothers who had completed pregnancy in the 5 years before the start of the program; and REACH-Futures71,72 used historic controls of nurse home visits. Outcomes were typically assessed months to years after the interventions.

Table 15 CHW maternal and child interventions and prenatal care and perinatal outcomes

Author, Year Study Design Population Setting Sample Size Quality | Intensity of CHW Intervention | Study Groups | Results
Graham et al., 1992^79^ RCT Pregnant inner-city African-American women Cleveland, Ohio N: 145 Fair | High | G1: Home visits with psychosocial support and encouragement, education, link to community resources, information on health risks; 4 visits of 1 hour each at 2–4 week intervals G2: Routine prenatal obstetric care (control) | No statistically significant difference between groups in incidence of low birth weight: 12.9% intervention, 7.5% controls (P = 0.51)
Nacion et al., 2000^72^ Cohort REACH-Futures Low-income inner-city African-American pregnant women and infants Chicago, Illinois N: 213 Fair | High | G1: Home visits by CHW G2: Home visits by nurse (historic control) | G1 more likely than G2 to receive problem- solving services (P < 0.01) and to have problems identified in women’s health (P = 0.01), well-child health care deficits (P = 0.02), parenting (P = 0.02), and socioeconomic issues (P < 0.01) G1 less likely than G2 to receive emotional support services (P < 0.01), to have referrals placed for women’s health (P = 0.01), well-woman (P = 0.02), emotional/interpersonal (P < 0.01), parental support (P < 0.01), or for socioeconomic issues (P < 0.01)
St. James et al., 1999^83^ Cohort Mothers with PKU New England N: 69 Fair | High | G1: Historic control; women who completed pregnancy in the 5 years prior to project onset G2: Resource mothers | Metabolic control achieved in 8.5 weeks for G2 vs. 16 weeks for G1 (P < 0.05) Infant mental scale on Bayley Developmental Quotient was 108 for G2 vs. 95 for G1 (P < 0.05) No difference in head circumference at birth (P = 0.08)
Barnes-Boyd et al., 2001^71^ Cohort REACH-Futures Low-income inner-city African-American pregnant women and infants Chicago, Illinois N: 1,922 Poor | High | G1: Monthly home visits over 1 year; visits at prenatal, 1, 6, and 12 months teamed with nurse G2: Historic controls with nurse home visits | Proportion fully immunized at 12 months: CHW 77%, nurse 63% (P < 0.001) No significant difference between groups in presence of neonatal or postneonatal health problems (27% CHW vs. 25% nurse)
Caulfield et al., 1998^77^ RCT African-American women receiving prenatal care Baltimore, Maryland N: 548 Poor | High | G1: Standard WIC services only G2: WIC plus video and literature G3: WIC plus peer counseling G4: WIC plus peer counseling plus video and literature | Initiation of breastfeeding: G1: 26% (referent) G2: 50% (OR, 1.36; 95% CI, 0.52–3.54) G3: 62% (OR, 3.84; 95% CI, 1.44–10.21) G4: 52% (OR, 1.92; 95% CI, 0.78–4.76) Breastfeeding at 7–10 days: G1: 14% (referent) G2: 30% (OR, 0.79; 95% CI, 0.25–2.52) G3: 38% (OR, 1.11; 95% CI, 0.34–3.61) G4: 38% (OR, 1.52; 95% CI, 0.50–4.59)
Tessaro et al., 1997^86,87^ Cohort Maternal Outreach Workers Medicaid-eligible pregnant women with 1 or more pregnancy risk factors North Carolina N: 705 Poor | High | G1: CHW intervention G2: Matched controls, not otherwise defined | Maternal depression score increased by 2.1 in G1 vs. 5.1 in G2 (P = 0.01) Prenatal care, African Americans: G1: 60.7% adequate, 32.6% intermediate, 6.7% inadequate G2: 63.8% adequate, 31.5% intermediate, 4.7% inadequate Prenatal care, Whites: G1: 77.4% adequate, 19.7% intermediate, 2.9% inadequate G2: 75.1% adequate, 22.8% intermediate, 2.1% inadequate No difference between groups in maternal self-esteem (P = 0.19) or perceived stress (P = 0.75) No difference in observed vs. expected incidence of low birth weight or very low birth weight: African Americans −13 (P = 0.12), Whites +1 (P = 0.58)

CHW, community health worker; PKU, phenylketonuria; WIC, Special Supplemental Nutrition Program for Women, Infants, and Children.

Overview of results. Improvements over usual care were demonstrated to be associated with CHWs in breastfeeding,77 maternal control of PKU,83 and prenatal care.86,87 However, birth outcomes in mothers with PKU,83 low birth weight incidence,86,87 continuation of breastfeeding,77 and overall presence of infant health problems71 were not significantly improved by use of CHWs compared with usual care77,83,86,87 or with health professional intervention.71

Knowledge. No study measured knowledge-related outcomes.

Behavior. No study assessed behavior change.

Health outcomes. Peer CHW counseling in the Baltimore study was associated with greater initiation of breastfeeding than standard care (OR, 3.84; 95 percent CI, 1.44–10.21), but the statistically significant difference between groups in the proportion of participants still breastfeeding by 7 to 10 days disappeared.77 For the Resource Mothers Program,83 mothers receiving the CHW intervention needed less time to reach metabolic control (blood phenylalanine level consistently below 10 mg/dL) than those who had not received the intervention (8.5 weeks versus 16 weeks, P < 0.05). The head circumference of infants born to participating mothers did not differ significantly between cohorts (mean Z-score of head circumference: intervention −0.56; 95 percent CI, −0.88 - −0.24 versus control –1.4; 95 percent CI, −1.56 - −1.2; P = 0.08). The Maternal Outreach Workers program demonstrated a trend toward lower incidence of adequate prenatal care for African-American women receiving CHW intervention than for controls (significance not reported);86,87 neither the observed nor the expected incidences of low birth weight or very low birth weight infants differed significantly. REACH-Futures found no difference between CHW intervention and controls in incidence of neonatal or postneonatal infant health problems.71

Health care utilization. The Cleveland study showed a significant increase in the ratio of actual to expected numbers of prenatal visits for women receiving CHW intervention (P = 0.029);79 the investigators did not compare the intervention findings to those from women in the control group.

Other. The fair-quality analysis from REACH-Futures found that CHW home visits were more likely than nurse home visits to include identification of problems in women’s health (P = 0.01), deficits in well-child care (P = 0.02), parenting issues (P = 0.02), and socioeconomic issues (P < 0.01) and that participants were more likely to receive problem-solving services (P < 0.01).72 However, CHWs were less likely than nurses to provide emotional support services (P < 0.01) or to place referrals for women’s health (P = 0.01), well-woman care (P = 0.02), emotional/interpersonal support (P < 0.01), parental support (P < 0.01), or socioeconomic issues (P < 0.01).

Maternal and child health: Child development. Study characteristics. Four studies considered the impact of CHWs on child development (Table 16). Three were rated fair quality and one poor quality; all used high-intensity interventions. One RCT focused on children with nonorganic failure to thrive in Baltimore, Maryland;75,76 another RCT examined the Home Visitation 2000 program in Denver, Colorado;80–82 and a cohort study involved the Resource Mothers Program for Maternal PKU in New England.83 The RCT assessing the Hawaii Healthy Start Program78,128 was rated poor for high potential for site-specific bias.

Table 16 CHW maternal and child interventions and child development

Author, Year Population Setting Sample Size Quality | Intensity of CHW Intervention | Study Groups | Results
Black et al., 1995;^75^ Hutcheson et al., 1997^76^ Low-income urban children with nonorganic failure to thrive Baltimore, Maryland N: 130 Fair | High | G1: Weekly CHW home visits with community health nurse supervision for 1 year, addressing various child health and development needs, nutrition intervention, and concerns raised by mothers G2: Clinic-based multidisciplinary services; no CHW intervention | Smaller postintervention decline in cognitive and motor development for G1 vs. G2 only for children recruited in infancy Bayley cognitive development (SD): G1: 96.9 (SD 15.8) to 89.3 (17.4) G2: 96.2 (12.1) to 86.1 (18.7) Bayley motor development: G1: 91.1 (18.7) to 92.0 (14.6) G2: 95.3 (17.7) to 91.5 (18.7) (P = 0.02) No significant differences between groups for language development
Korfmacher et al., 1999;^81^ Olds et al., 2002;^80^ Olds et al., 2004^82^ Home Visitation 2000 Medicaid-eligible pregnant women Denver, Colorado N: 735 Fair | High | G1: Developmental screening plus intensive home visitation: promoting healthy behaviors, competent child care, pregnancy planning, education, employment; linking to social and health services; promoting healthy family/friend relationships; variable frequency from weekly to monthly up to 24 months of age G2: Developmental screening plus nurse home visits G3: Developmental screening and referrals | Preschool Language Scales at 21 months (G3 mean 99.49): G1 vs. G3 +0.40 (95% CI, −1.94 to +2.74) G2 vs. G3 +1.73 (95% CI, −0.64 to +4.11) Mental Development Index at 24 months (G3 mean 89.38): G1 vs. G3 +0.07 (95% CI, −2.39 to +2.53) G2 vs. G3 +0.75 (95% CI, −1.77 to +3.28)
St. James et al., 1999^83^ Mothers with PKU (PKU Resource Mothers Program) New England N: 69 Fair | High | G1: Historic control; women who completed pregnancy in the 5 years before project onset G2: Resource mothers | Infant mental scale on Bayley Developmental Quotient was G1: 95 G2: 108 (P < 0.05)
Duggan et al., 1999;^128^ Duggan et al., 2000^78^ Families at high risk for child maltreatment Oahu, Hawaii N: 730 Poor | High | G1: Home visiting with individualized service plans, child developmental screenings, and mother-child interaction assessments; family support plan within 45 days of initial visit, reviewed every 6 months, revised annually; periodic screening for developmental delays, observational assessment of parent-child interaction and home environment; ensure existence of medical home, link to other needed resources G2: Control (details NR) | All outcome measures at 2 years postintervention Bayley Scales of Infant Development – Mental Development Index: G1: 90.0 G2: 89.2 (P = 0.60) Psychomotor Development Index: G1: 92.1 G2: 90.4 (P = 0.12)

CHW, community health workers; CI, confidence interval; G, group; PKU, phenylketonuria; SD, standard deviation.

Overview of results. Variation in timing and specific outcomes among studies precludes much summarization of results. Two of the studies demonstrated some significant benefit of CHW intervention over usual care; the other two showed no significant difference between CHW intervention and controls. The failure-to-thrive study demonstrated that the CHW home visiting program was effective in mitigating declines in cognitive and motor development, but not language, if implemented during the first year of life (Table 16).75,76 The PKU Resource Mothers Program study found higher mental development for infants born to mothers who participated than for those born to historic controls.83 By contrast, the Home Visitation 2000 trial showed more improvement in language development with nurse visits rather than CHWs,80–82 and the Hawaii trial found no difference in mental or psychomotor development between children receiving CHW intervention and controls.

Knowledge. No study assessed knowledge about child development issues.

Behavior. No study included health behaviors in the outcomes measured.

Satisfaction. No study considered satisfaction outcomes.

Health outcomes. All four studies examined various health outcomes. In the Baltimore, Maryland, failure-to-thrive study, the decline in cognitive development over 1 year as measured by the Bayley Scales of Infant Development was less severe for the home intervention group than for the clinic-only group (P = 0.02) for children recruited during infancy. Groups of children recruited at older ages did not differ using the Battelle Developmental Inventory, although all groups demonstrated some degree of decline in cognitive function. Whether this decline was attributable to failure to thrive or to some other factor was not assessed in the study. Children in the intervention group showed less severe decline in receptive and expressive language than did age-matched controls (P = 0.05), but all groups experienced relative declines in language over the course of the study. All groups showed significant improvements in weight for age, weight for height, and height for age, but the groups did not differ significantly.

The Home Visitation 2000 study in Denver, Colorado, found slightly greater improvement over controls with nurse home visits than with CHW visits for the Preschool Language Scales at 21 months and the Mental Development Index at 24 months.80–82

Infants in the intervention cohort of the Resource Mothers Program in New England had higher mean Bayley Developmental Quotient (mental scale) values than those in the control cohort (108 versus 95) at 12 months of age (P < 0.05).83

At 2 years postintervention, children in the Hawaii Healthy Start Program78,128 who received CHW intervention had a mean Bayley Mental Development Index score of 90.0 versus 89.2 for controls (P = 0.60) and a Psychomotor Development Index score of 92.1 versus 90.4 for controls (P = 0.12).

Health care utilization. No study assessed health care utilization.

Maternal and child health: Environment conducive to child well-being. Study characteristics. Factors contributing to an environment conducive to the health and well-being of children were assessed directly in 10 studies; 6 rated as fair quality and 4 as poor quality. The five fair-quality RCTs covered the following populations and interventions: smokers in San Diego;67 low-income urban children with nonorganic failure to thrive;75,76 the Parent to Parent Network for mothers of children with chronic conditions;85 a trial targeting children in New York with missed immunization visits;68 a trial involving drug-using mothers in Maryland;84 and the Home Visitation 2000 RCT.80–82 Finally, of the four poor-quality studies, two RCTs (both involving the Child-Parent Enrichment Project, or CPEP73,74) were rated poor for lack of relevant outcome measures; the Hawaii Healthy Start Program78,128 was rated poor for high potential for site-specific bias; and on the REACH-Futures trial71 was rated poor because of high potential for secular trend and for other confounding.

Overview of results. The variety of outcomes assessed by the studies precludes much summary of results. Of the 10 studies in this category, only 4 reported significantly beneficial outcomes for CHWs over usual care.

The New York study68 and REACH-Futures trial71 did find CHW-associated improvements in immunization status. Home Visitation 2000 showed greater improvement with nurse than with CHW interventions for mother-infant interaction, home environment, and tobacco smoke exposure.80–82 The Hawaii study found that CHW intervention significantly increased appropriate parental coping and discipline methods and decreased injuries from partner-related violence.78,128

As to the remaining studies: the San Diego study found no significant impact by CHWs on exposure to environmental tobacco smoke among children of smokers.67 The failure-to-thrive study found no effect of CHWs on outcomes related to home environment or parenting behavior.75,76 The Parent to Parent Network study showed no significant difference between intervention and control groups for maternal psychiatric well-being postintervention;85 however, the results were potentially confounded by differences at baseline. No differences were found in the Maryland study84 for maternal drug use or mother-child interaction. Other studies on substance abuse, child maltreatment, and improving psychiatric outcomes among caregivers of children with chronic diseases also did not report significant differences between study arms.74,84

Knowledge. No study assessed measures of knowledge.

Behavior. The failure-to-thrive study found no differences between groups for parent-child interaction behavior during feeding using a modified Parent Child Early Relational Assessment.75,76 It did show improved interactive communication with parents during feeding among children over time for all groups (P < 0.001), but no differences were apparent according to intervention status. Developmental appropriateness of the home environment, as assessed postintervention by the Home Observation for Measurement of the Environment Scales, was slightly higher for the CHW intervention group than for the clinic-only group (31.6 [SD 3.6] versus 29.3 [SD 4.2] for infants; 32.4 [SD 5.1] versus 30.3 [SD 5.7] for older children; P = 0.05 [significance not reported by age strata]). However, no baseline scores were reported for this measure to ascertain the true effect of CHWs.

In the Maryland study on substance-abusing mothers, self-reported postintervention substance use was similar for mothers receiving CHW interventions and for those in the control group (65 percent versus 68 percent for alcohol, 46 percent versus 44 percent for cocaine and/or heroin, and 25 percent versus 38 percent for marijuana; P ≥ 0.1).84

The Hawaii study found that parents who received CHW intervention had a greater postintervention use of nonviolent discipline strategies (see Table 16), reported less parenting-related stress, and had higher parenting efficacy scores than those receiving usual care alone.78,128

Satisfaction. No study assessed satisfaction outcomes.

Health outcomes. Among children of smokers in the San Diego study,67 no reduction was seen in parental report of children’s tobacco exposure or in nicotine or cotinine levels in children’s hair for either CHW or control participants. The Parent to Parent Network demonstrated no difference between groups in postintervention Psychiatric Symptom Index scores (intervention 22.1 versus control 20.1).85 However, the baseline score for the intervention group was significantly higher than for the control group (24.1 versus 20.3, respectively; P < 0.05). Adjustment for this baseline difference revealed a greater degree of improvement in the intervention group than in controls, except for the depression subscale, which was improved in both groups. However, whether this reflected true improvement attributable to CHWs or was simply a regression to the mean could not be determined. The New York study showed that children receiving CHW intervention were more likely than control children to be current on their immunizations (P = 0.03) and less likely to have received immunizations behind schedule (P < 0.05) (Table 17).68

Table 17 CHW maternal and child interventions and environment conducive to child health

Author, Year Study Design Population Setting Sample Size Quality | Intensity of CHW Intervention | Study Groups | Results
Barnes et al., 1999^68^ Low-income immigrant children from Dominican Republic NW Manhattan, New York N: 434 Fair | High | G1: Basic immunization education and referral; home visits with reminders of immunizations due, followup to ensure compliance G2: Information provided on child’s missed immunizations, encouraged to reschedule missed appointments (control) | Immunizations up to date: G1: 75% G2: 54% (P = 0.03) Late for immunizations: G1: 18% G2: 38% (P < 0.05)
Conway et al., 2004^67^ Latino families with smokers and children between 1 and 9 years old San Diego County, California N: 143 Fair | High | G1: Home and telephone visits on problem-solving techniques to reduce environmental tobacco smoke exposure; 6 visits over 4 months G2: Participated in surveys but received no other intervention (control) | No difference between groups for parent report of child’s tobacco exposure or child’s hair nicotine or cotinine levels (no reduction in either group)
Black et al., 1995^75^; Hutcheson et al., 1997^76^ Low-income urban children with nonorganic failure to thrive Baltimore, Maryland N: 130 Fair | High | G1: Weekly CHW home visits with community health nurse supervision for 1 year, addressing various child health and development needs, nutrition intervention, and concerns raised by mothers G2: Clinic-based multidisciplinary services; no CHW intervention | No significant differences between groups for parent-child interaction HOMES home environment scores not reported pre-intervention
Korfmacher et al., 1999;^81^ Olds et al., 2002;^80^ Olds et al., 2004^82^ (Home Visitation 2000) Medicaid-eligible pregnant women Denver, Colorado N: 735 Fair | High | G1: Developmental screening plus intensive home visitation: promoting healthy behaviors, competent child care, pregnancy planning, education, employment; linking to social and health services; promoting healthy family/friend relationships; variable frequency from weekly to monthly up to 24 months of age G2: Developmental screening plus nurse home visits G3: Developmental screening and referrals (control) | Greater improvement in mother-infant interaction and home environment with intervention vs. controls for nurse home visits (least squares mean 1.32, P ≤0.05) than for CHW visits (least squares mean 1.16, P < 0.1) Urine cotinine among smoking mothers reduced in all groups, more so for nurse intervention: CHW vs. control −76.19 ng/dL (95% CI, −302.21 to −149.82) Nurse vs. control −246.68 ng/dL (95% CI, −466.19 to −27.16; P ≤ 0.05)
Schuler et al., 2000^84^ Women with known history of drug use plus their infants Unspecified inner city, Maryland N: 192 Fair | High | G1: 9 visits of 30 minutes each to enhance mothers’ ability to manage self-identified problems by using existing services and family and social supports; modeling infant development behavior/activities G2: 3 monthly visits of 17 minutes each for tracking purposes only | No difference between groups in self- reported maternal drug use or in infant warmth on observed mother- child interactions 65% of intervention and 68% of controls reported alcohol use postintervention, 46% of intervention and 44% of controls reported cocaine and/or heroin use, 25% of intervention and 38% of controls reported marijuana use (P ≥ 0.1)
Silver et al., 1997^85^ Inner-city, low-income, minority women with children who have a chronic disease Bronx or Lower Westchester, New York N: 365 Fair | High | G1: Intervention G2: Usual care (control) | Psychiatric Symptom Index scores higher at baseline in G1 than G2 (P < 0.05), but no difference between groups postintervention
Barnes-Boyd et al., 2001^71^ (REACH-Futures) Low-income inner-city African-American pregnant women and infants Chicago, Illinois N: 1,922 Poor | High | G1: Monthly home visits over 1 year; visits at prenatal, 1, 6, and 12 months teamed with nurse G2: Nurse home visits (historic controls) | Proportion fully immunized at 12 months: CHW 77%, nurse 63% (P < 0.001)
Barth et al., 1988^73^ Families referred for high risk of child maltreatment Contra Costa County, California N: 65 Poor | High | G1: Twice-monthly home visits over 6 months with links to other community resources G2: Usual care | Child Abuse Potential Inventory pre- vs. postintervention: G1: 116.33 (SD 47.75) to 88.54 (SD 53.09) G2: 103.50 (SD 43.26) to 92.44 (SD 51.44) (P ≥ 0.05 between groups)
Barth et al., 1991^74^ Families referred for high risk of child maltreatment Contra Costa County, California N: 240 Poor | High | G1: Home visits G2: Usual care | Increase in total child maltreatment- related reports and court actions: G1: +40 families to +65 total reports G2: +41 families to +74 total reports (no significance testing reported)
Duggan et al., 1999;^128^ Duggan et al., 2000^78^ Families at high risk for child maltreatment Oahu, Hawaii N: 730 Poor | High | G1: Home visiting with individualized service plans, child developmental screenings, and mother-child interaction assessments; family support plan within 45 days of initial visit, reviewed every 6 months, revised annually; periodic screening for developmental delays, observational assessment of parent-child interaction and home environment; ensure existence of medical home, links to other needed resources G2: Control (details NR) | All outcome measures at 2 years postintervention Reported frequent use of nonviolent discipline strategies: G1: 39% G2: 34% (P = 0.03) Reported parenting-related stress: G1: 77.7% G2: 80.7% (P = 0.08) Parenting efficacy (Parenting Sense of Confidence Scale): G1: 76.1 G2: 74.1 (P = 0.03) Maternal life skills (Community Life Skills Scale): G1: 23.9 G2: 23.9 (P = 0.84) Maternal social support (Maternal Social Support Index): G1: 21.4 G2: 21.7 (P = 0.48) Maternal substance use: G1: 18% G2: 20% (P = 0.55) Maternal depressive symptoms: G1: 23% G2: 26% (P = 0.49) Poor, general maternal mental health: G1: 36% G2: 39% (P = 0.43) Home learning environment (Total Home Observation for Measurement of the Environment Scale): G1: 34.6 G2: 34.1 (P = 0.47) Mother-child interaction (Nursing Child Assessment Satellite Training scales): G1: Caregiver total 15.0, child total 7.2 G2: Caregiver total 14.6 (P = 0.28), child total 7.2 (P = 0.83) Partner-related violence in household resulting in injury: G1: 16% G2: 24% (P = 0.03) Confirmed Child Protective Services reports: G1: 2% G2: 3% (P = 0.40) Presence of primary care provider: G1: 91% G2: 86% (P = 0.09) Adequate number of well-child visits: G1: 60% G2: 55% (P = 0.95) Immunizations up to date: G1: 87% G2: 85% (P = 0.45)

CHW, community health worker; CI, confidence interval; G, group; N, number; ng/dL, nanograms/deciliter; SD, standard deviation.

The Maryland study found infant warmth (on a 5-point scale) to be equal for those receiving CHW interventions and controls (2.5, SD 0.4 for both groups).84

Home Environment 2000 demonstrated more improvement over controls in mother-infant interaction and in home environment for nurse home visits (least squares mean 1.32, P ≤ 0.05) than for CHW visits (least squares mean 1.16, P < 0.1).80–82 Among participating families with mothers who smoked, maternal urine cotinine was reduced in all groups; those receiving nurse home visits had a significantly greater degree of reduction than those receiving CHW visits (nurse versus control −246.68 ng/dL; 95 percent CI, −466.19 to −27.16); CHW versus control −76.19 ng/dL; 95 percent CI, −302.21 to −149.82; P ≤ 0.05).

The studies from Contra Costa, California, found no significant difference between groups on the Child Abuse Potential Inventory postintervention (Table 17); both groups showed improvement and no difference in reported cases of child maltreatment.73,74

The Hawaii study78,128 demonstrated no difference between groups for maternal life skills (Table 17), maternal social support, maternal substance use, maternal depressive symptoms, or incidence of poor general mental health among mothers at 2 years postintervention. Neither home learning environment nor parent-child interactions differed between groups at 2 years. The investigators did not report how each of these measures compared with baseline values. The study did show lower incidence of injuries attributable to partner-related violence among families receiving CHW intervention (P = 0.03), but no differences in reported or confirmed cases of child maltreatment.

Health care utilization. Children receiving CHW intervention in the Hawaii study were no more likely than those receiving usual care to have a primary care provider (P = 0.09) (Table 17), to have received the recommended number of well-child visits (P = 0.95), or to be current on immunization status (P = 0.45).78,128

### Outcomes for Cancer Screening

Cancer screening. Study Characteristics. A total of 15 studies (24 citations) examined outcomes of CHW interventions for improving breast, cervical, or colorectal cancer screening.15,17–22,59–63,103,104,106–113,116,125 Information on these studies is spread across multiple tables, depending on the specific focus: improving knowledge, changing behavior, breast self-examination, Pap smears, mammography, clinical breast examination, and colorectal cancer screening.

Of these studies, 10 are RCTs15,17–22,61–63,103,104,106–113 and 5 are observational studies.59,60,108,113,116,125 The RCTs include three randomized by communities103 or churches.19–22,104,107 Of the five observational studies, one was a quasi-experimental controlled cohort,125 two were prospective cohorts,108,113 one used retrospective records,59,60 and one used repeated cross-sectional survey of women attending beauty salons randomly assigned to experimental and control groups.116 The studies spanned the quality range as well: two were of good quality,17,18,103 seven of fair quality,59–63,106,108,109,125 and six of poor quality.15,19–22,104,107,110–113,116

As noted in our section on KQ 1, seven studies used low-intensity CHW models, 6 used moderate-intensity interventions, and two used high-intensity interventions. Six studies included more than two arms. Studies compared the CHW arm with a variety of alternatives, including no intervention or usual care (6 studies), mail (3 studies), community interventions (4 studies), CHWs in a lesser capacity (2 studies), and CHWs in combination with other interventions (2 studies).

With the exception of two studies on colorectal cancer screening,106,107 all other studies focus on women. All studies focused mainly on minority or underserved communities.

Studies used varied definitions of outcomes. The greatest commonality was reporting on utilization of cancer screening tests such as mammography, clinical breast examination, Pap smears, and colorectal cancer screening. Of the 15 studies, 13 reported on changes in rates of utilization, but they varied in their specific definitions (ever use, use in the past 3 months, 1 year, 2 years, and so on).15,17–22,59–63,104,106–113,125 With the exception of 3 studies examining Medicaid or medical records for mammography use,17,18,59,60,63 all relied solely on self-report.

Overview of results. Together, the 15 studies suggest limited evidence of improvement in knowledge in the CHW arm compared with alternative approaches; they present conflicting findings on the effect of CHWs on planned and actual health behaviors, specifically breast self-examination. The volume of evidence on these outcomes is limited; the quality and design of the studies limits the interpretation of available evidence.

Unlike most of the other subsections dealing with other purposes for CHW strategies, cancer screening studies used high-, moderate-, and low-intensity interventions. Enough studies and evidence are available to permit some analysis by the intensity variable as it relates to Pap smears and mammography. Summary tables for these two outcomes are therefore presented by intensity (low, then moderate, then high), followed by quality, and then alphabetical order, by last name of first author(s); for all other sections, we present studies by quality, and then alphabetical order, by last name of first author(s).

Regarding health care utilization, our findings from this limited evidence do not support the conclusion that CHW interventions are more effective in comparison with other alternatives in raising the rates of clinical breast examination or colorectal cancer screening. More substantial evidence exists on Pap smears and mammography. The CHW approach is at least as effective as the alternative in improving Pap smear rates, but it is more effective than the alternative only in limited circumstances of low- and moderate-intensity interventions. With respect to mammography rates, studies demonstrated significantly greater improvements in the CHW arm compared with the alternative (no intervention, mail, print, or minimal CHW) in either the entire sample or in subsamples.

Knowledge. Two studies (three articles; Table 18) examined changes in knowledge and found limited evidence of improvement for the CHW arm.17,18,109 A good-quality, high-intensity study in North Carolina measured knowledge for 12 individual measures on breast cancer and a composite score.17,18 The studies together suggest improvements in the CHW arm, although the results are not consistent on the relative benefit of the CHW arm versus the alternative. Although differences between the CHW and the comparison arm (mail intervention) were not statistically significant for the composite measure of knowledge, the study reported significant different improvements favoring the CHW arm on two individual items measuring knowledge. Both arms demonstrated improvements in other measures, but these improvements were not statistically significantly different. A second study, of fair quality and moderate intensity in California, found significantly different improvements on two measures of knowledge, favoring the CHW arm compared with the media intervention arm.109

Table 18 CHW cancer screening: improving knowledge

Author, Year Study Design Population Setting Sample Size Quality | Intensity of CHW Intervention | Study Groups | Results
Paskett et al., 2006;^17^ Katz et al., 2007^18^ RCT Community health centers, Robeson County, North Carolina 820 Good | High | G1: Letter and NCI brochure sent about the need for regular cervical cancer screening 6 months after random assignment, followed by letter and NCI brochure about the need for mammography 3 months after followup assessment (control) G2: Individualized health education program that was culturally acceptable and tailored to meet the needs of each woman, intensive face-to-face interactive educational program administered over a 9- to 12-month period, consisting of 3 in- person visits, with educational materials provided at each visit and followup telephone calls and mailings thereafter | Composite knowledge score: not statistically significantly higher in CHW group
Mock et al., 2007^109^ RCT Vietnamese-American women, Santa Clara County, California 968 Fair | Moderate | G1: CHW small group meetings; direct contact with subjects; Vietnamese language ads for TV, radio, newspaper; booklets and printed materials in various community locations G2: Vietnamese-language ads for TV, radio, newspaper; booklets and printed materials in various community locations; delayed educational session | Reported awareness of need for Pap test by women 18+ years old (baseline/followup): G1: 68.4%/93.9% (P < 0.001) G2: 68.5%/70.2% (P = 0.55) Z-test P < 0.001 Heard of Pap test: G1: 81.8%/99.6% (P < 0.001) G2: 87.2%/95.2% (P < 0.001) Z-test P < 0.001

CHW, community health workers; G, group; NCI, National Cancer Institute; RCT, randomized controlled trial; TV, television.

Behavior: planned testing. Two studies, one of fair quality and low intensity63 and the other of poor quality and moderate intensity,116 provide contradictory findings on the effect of CHWs on planned behavior Table 19). The fair-quality study compared a CHW arm with direct and usual care; differences in the rate of planned Pap smear tests favoring the CHW arm were statistically significant compared with either direct mail or usual care.63 The poor-quality study reported no differences among study arms. However, the design of the study, which involved repeated cross-sections in salons randomly assigned to experimental and control status in which experimental salons offered barrier-specific counseling, was not measuring changes in intent over time; rather, it was concerned with differences in a cross-sectional sample. Low penetration combined with contamination across the samples (as suggested by the 37 percent and 10 percent of the sample reporting breast health messages at control sites and experimental sites, respectively) could have diluted the effects of the intervention.116

Table 19 CHW cancer screening: changing planned behaviors

Author, Year Study Design Population Setting Sample Size Quality | Intensity of CHW Intervention | Study Groups | Results
Taylor, et al., 2002^63^ RCT Chinese-American women, Seattle, Washington, and Vancouver, British Columbia 402 (181 Seattle, 221 Vancouver) Fair | Low | G1: Introductory mailing, CHW visit with multimedia and tailored counseling, telephone followup and tailored counseling, logistic assistance as needed G2: Direct mail multimedia materials G3: Usual care at local clinics and doctors' offices (control) | Pap testing planned within 2 years: G1: 72% G2: 59% G3: 48% (G1 vs. G3 P < 0.001, G2 vs. G3 P = 0.05, G1 vs. G2 P = 0.03)
Wilson et al., 2008^116^ Repeated cross- sectional survey of women attending salons randomly assigned to experimental and control groups Neighborhood hair salons, Brooklyn, New York 40 salons/1,210 respondents Poor | Moderate | G1: Control, before intervention G2: Stylist group, before intervention G3: Control, after intervention G4: Stylist group, after intervention Intervention consisted of education, counseling, and information on location of screening services during salon appointment | Intention to receive clinical breast examination in next year: G3: 90% G4: 89% AOR, 0.9; adjusted 95% CI, 0.6–1.2 Intention to receive mammogram in next year: G3: 70% G4: 74% AOR, 1.3; adjusted 95% CI, 0.9–1.2

CHW, community health worker; CI, confidence interval; G, group; AOR, adjusted odds ratio.

Behavior: breast self-examination. Five studies (eight citations; Table 20) reported on changes in self-breast examination as outcomes of CHW interventions.61,62,108,110–112,116,125 Of these five studies, three were of fair quality61,62,108,125 and two of poor quality.110–112,116 They included one high-intensity,61,62 three moderate-intensity,110–112,116,125 and one low-intensity study.108

Table 20 CHW cancer screening: changing breast self-examination behavior

Author, Year Study Design Population Setting Sample Size Quality | Intensity of CHW Intervention | Study Groups | Results
Erwin et al., 1997^108^ Prospective cohort Church or community groups, rural Mississippi River Delta region, Arkansas 412 Fair | Low | G1: Members of a Witness Project team, composed of 7 local African-American women who had survived breast or cervical cancer, spoke in groups of 2 to 5 at local churches and community organization meetings G2: Delayed intervention (control) | Regular practice of BSE (self-report): G1: 69.8% to 82% (P < 0.005 compared with baseline) G2: 82% to 82% (P = NS compared with baseline) BSE in the past month (self-report): G1: 49% to 65.4% (P < 0.001 compared with baseline) G2: 65% to 72% (P = NS compared with baseline)
Hiatt et al., 2008^125^ Prospective cohort Public health clinics and the low-income neighborhoods in San Francisco and Contra Costa County, California 1,616 Fair | Moderate | G1: One-on-one visits at various events and locations; presentations to community-based organizations (agencies); and Women’s Health Days, offering free mammograms, Pap tests, and breast self-examination instruction G2: No intervention (control) | Ever completed breast self-examination (Total N [%] pretest/Total N [%] posttest): G1: 800 (89)/810 (92) Χ ^2^ = NR, P=0.031 G2: 793 (83)/802(81) Χ ^2^ = NR, not significant Completed breast self-examination monthly in the past year (Total N [%]pretest/Total N [%] posttest): G1: 800 (24)/808 (26) Χ ^2^ = NR, not significant G2: 793 (18)/801(23) Χ ^2^ = NR, P=0.018
Sung et al., 1997^61^; Sung et al., 1992^62^ RCT Inner-city African Americans, state unspecified 195 Fair | High | G1: CHW home visits, education on breast and cervical cancer, BSE educational materials on screening, facilitation to address logistical barriers to screening G2: Mailed educational materials on cancer screening | Pretest/posttest change in self-report of BSE for entire sample: G1: 52.1%/51.0% G2: 41.1%/41.0%, difference in change: −1.0 (95% CI, −6.1 to 4.1) Pretest/posttest change in self-report of BSE, postintervention respondents only: G1: 57.0%/53.8% G2: 40.2%/40.2%, difference in change: −3.2 (95% CI, −17.5 to 11.1) Posttest report of BSE, women not previously on recommended screening schedules, whole sample: G1: 24.4% G2: 17.2%, difference in change: 7.2% (95% CI, −5.0–19.3) Posttest report of BSE, women not previously on recommended screening schedules, postintervention respondents only: G1: 47.5% G2: 26.2%, difference in change: 21.3% (95% CI, 2.3–40.3)
Navarro et al., 1998,^111^ Navarro et al., 1995,^110^ Navarro et al., 2000^112^ RCT Low-income Latinas, Southeast San Diego County, California 365 Poor | Moderate | G1: CHW delivering community living skills sessions, details NR G2: CHW delivering cancer education sessions, 12 weekly group sessions conducted over 3 months plus 2 additional sessions offered within a year of beginning of group meetings | Pretest-posttest changes in percentage of women performing monthly BSEs: Participant unit of analysis (n = 361) G1: 18.5 G2: 33.2 P < 0.001 t = 3.23 CHW unit of analysis (n = 35) G1: 18.6 G2: 31.8 P = 0.021 t = 2.43 Odds of monthly BSE at 1-year and 2-year followup for cancer screening group (P value): Year 1: 2.03 (0.016) Year 2: 0.96 (0.877)
Wilson et al., 2008^116^ Repeated cross-sectional survey of women attending salons randomly assigned to experimental and control groups Neighborhood hair salons, Brooklyn, New York 40 salons/1,210 respondents Poor | Moderate | G1: Control, before intervention G2: Stylist group, before intervention G3: Control, after intervention G4: Stylist group, after intervention Intervention: provide messages promoting breast health during salon visit | Engaging in BSE in past 3 months: G1: 25% G2: 28%, P = 0.26 for differences between G1 and G2 G3: 37% G4: 40% AOR for differences between G3 and G4 1.3; adjusted 95% CI, 0.9–1.7

AOR, adjusted odds ratio; BSE, breast self examination; CHW, community health worker; CI, confidence interval; G, group; NR, not reported; NS, not significant; OR, odds ratio; RCT, randomized controlled trial.

These studies provide conflicting evidence of the effectiveness of the CHW approach, either in comparison with an alternative or over time independent of a comparison. Two studies reported significant differences between the CHW arm and an alternative (low-intensity CHW, mailed intervention, delayed intervention, or no intervention).108,110–112 The same two studies also provided evidence of significant differences between baseline and followup for the CHW arm.108,110–112 A third study employed repeated cross-sectional measurements and reported higher rates in the followup assessment but these were not statistically significant.116 The fourth study failed to find any improvements over time.61,62 The fifth study found reported conflicting results for the two selected measures.

Of the three fair-quality studies, the high-intensity study compared the CHW arm with a mailed intervention,61,62 the moderate-intensity study compared the CHW arm (outreach) to no-intervention arm, and the low-intensity CHW arm compared the CHW arm to a delayed intervention.108 The high-intensity study found no significant improvements over time in either arm, or between arms, except when the sample was restricted to a much reduced subsample who were available at followup and were not on the recommended screening schedule.61,62 The moderate-intensity study found improvements in the intervention arm over time for ever use of breast self-examination, but no significant differences in the control arm, but also found opposite effects for another measure: monthly breast self-examinations, with significant differences in the control arm over time, but not the intervention arm The low-intensity study found that the CHW arm resulted in significant improvements over time compared with the delayed-intervention arm.108 However, baseline differences between the two arms were large; significant differences between the two arms could have resulted from ceiling effects.

Of the two poor-quality studies, one moderate-intensity intervention compared a more intense CHW arm with a less intense CHW arm;110–112 the other moderate-intensity intervention compared the CHW arm with a no-intervention control.116 In the former study, the two arms differed significantly through 1-year followup but not at the 2-year followup.110–112 In the latter study, rates of breast self-examination were higher in followup interviews than in baseline interviews, but the differences between the arms was not statistically significant.116

Satisfaction. No study reported outcomes for satisfaction.

Health outcomes: No study reported on health outcomes.

Health care utilization: Pap smears. The evidence on the effectiveness of CHW interventions draws upon six studies (nine articles; Table 21).17,18,61–63,110–112 Most studies demonstrate that the CHW arm is as effective as the alternative in improving Pap smear rates. CHWs were notmore effective than mailed interventions in high-intensity interventions. They were more effective than the alternative in limited circumstances involving low- or moderate-intensity intervention in three of four studies. Because intensity may, thus, actually be an important policy variable for analyzing use of Pap smears, we present information on Pap smear use ordered first by intensity and then by the quality of the studies.

Table 21 CHW cancer screening: Pap smears

Author, Year Study Design Population Setting Sample Size Quality | Intensity of CHW Intervention | Study Groups | Results
Taylor, et al., 2002^63^ RCT Chinese- American women, Seattle, Washington, and Vancouver, British Columbia 402 (181 Seattle, 221 Vancouver) Fair | Low | G1: Introductory mailing, CHW visit with multimedia and tailored counseling, telephone followup and tailored counseling, logistic assistance as needed G2: Direct mail multimedia materials G3: Usual care at local clinics and doctors’ offices (control) | Self-reported Pap testing completed since intervention: G1: 39%, G2: 25%, G3: 15% (G1 vs. G3, P < 0.001; G2 vs. G3, P = 0.03; G1 vs. G2, P = 0.02) Medical records for Pap screening received between randomization and followup, using intention-to-treat: Results not provided, significant differences between outreach worker versus control (P <.001), direct mail versus control (P =.07), and outreach worker versus direct mail (P =.04) Medical records for Pap screening received in the past 2 years, using intention-to-treat: Results not provided, significant differences between outreach worker versus control (P <.001) and direct mail versus control (P =.03)
Hiatt et al., 2008^125^ Prospective cohort Public health clinics and the low-income neighborhoods in San Francisco and Contra Costa County, California 1,616 Fair | Moderate | G1: One-on-one visits at various events and locations; presentations to community-based organizations (agencies); and Women’s Health Days, offering free mammograms, Pap tests, and breast self-examination instruction G2: No intervention (control) | Ever completed Pap smear (logistic regression, 95% CI) Residence in outreach area over time: 1.5 (0.6–4.2) Completed Pap smear in the past 3 years (logistic regression, 95% CI) Residence in outreach area over time: 0.9 (0.6–1.3)
Mock et al., 2007^109^ RCT Vietnamese-American women, Santa Clara County, California 968 Fair | Moderate | G1: CHW small group meetings, direct contact with subjects, Vietnamese language ads for TV/radio/newspaper, booklets and printed materials in various community locations G2: Vietnamese-language ads for TV/radio/newspaper, booklets and printed materials in various community locations, delayed educational session | Self-report of having ever had Pap (baseline/followup): G1: 65.8%/81.8% (P < 0.001); G2: 70.1%/75.5% (P < 0.001); Z test P = 0.001 Self-report of Pap in past year: G1: 45.7%/67.3% (P < 0.001); G2: 50.9%/55.7% (P = 0.035); Z test P < 0.001 Ever had Pap test (among those who had not had Pap test pre-outreach): G1: 46.0 (N = 144); G2: 27.1 (N = 161) P < 0.001
Navarro et al., 1998;^111^ Navarro et al., 1995;^110^ Navarro et al., 2000^112^ RCT Low-income Latinas, southeast San Diego County, California 365 Poor | Moderate | G1: CHW delivering community living skills sessions, details NR G2: CHW delivering cancer education sessions, 12 weekly group sessions conducted over 3 months plus 2 additional sessions offered within a year of beginning of group meetings | Pretest-posttest changes in percentages of women who had a Pap test within past year: Participant unit of analysis (n = 360) G1: 16.2 G2: 23.1 P = 0.096 t = 1.67 CHW unit of analysis (n = 35) G1: 18.4 G2: 23.4 P = 0.369 t = 0.91 Odds of Pap smear 1-year and 2-year followup for cancer screening group (P value): Year 1: 2.10 (0.017) Year 2: 1.70 (0.082)
Paskett et al., 2006;^17^ Katz et al., 2007^18^ RCT Community health centers, Robeson County, North Carolina 820 Good | High | G1: Control sent letter and NCI brochure about the need for regular cervical cancer screening 6 months after random assignment, followed by letter and NCI brochure about the need for mammography 3 months after followup assessment G2: Individualized health education program that was culturally acceptable and tailored to meet the needs of each woman, intensive face-to-face interactive educational program administered over a 9- to 12- month period, consisting of 3 in- person visits, with educational materials provided each visit and followup telephone calls and mailings after | Cervical cancer screening rates within risk-appropriate guidelines: Significant differences between baseline and followup for both groups, no significant differences between intervention and control groups
Sung et al., 1997;^61^ Sung et al., 1992^62^ RCT Inner-city African Americans, state unspecified 195 Fair | High | G1: CHW home visits, education on breast and cervical cancer, breast self-exam, educational materials on screening, facilitation to address logistical barriers to screening G2: Mailed educational materials on cancer screening | Pretest/posttest change in self-report of receiving Pap smears for entire sample: G1: 50.3%/58.7% G2: 51.9%/62.1%, difference in change: −1.8 (95% CI, −8.0–4.4) Pretest/posttest change in self-report of receiving Pap smears, postintervention respondents only: G1: 52.7%/63.4% G2: 50.0%/62.7%, difference in change: −2.0 (95% CI, −11.0–7.0) Posttest rate of self-report of receiving Pap smears, women not previously on recommended screening schedules, whole sample: G1: 33.3% G2: 34.2%, difference in change: −0.9 (95% CI, −15.7–13.9) Posttest rate of self-report of receiving Pap smears, women not previously on recommended screening schedules, postintervention respondents only: G1: 61.4% G2: 51.0%, difference in change: 10.4 (95% CI, −9.5–30.0)

CHW, community health worker; CI, confidence interval; G, group; N, number; NCI, National Cancer Institute; NR, not reported; RCT, randomized controlled trial; TV, television.

One low-intensity trial, of fair quality, compared CHWs with direct mail and with usual care in cities in Washington and British Columbia.63 CHWs were more effective than either alternative in increasing Pap smear rates, using both self-report and medical records.

Of the three moderate-intensity interventions, one in Santa Clara County, California, was of fair quality109, a second in San Francisco and Contra Costa was also fair quality,125 and the third in San Diego County, California, was rated poor quality.110–112 The fair-quality study in Santa Clara compared CHWs with a media intervention; CHWs were effective in increasing rates of Pap smears.109 The fair-quality study in San Francisco and Contra Costa found no statistically significant difference in changes in self-reported Pap smears between residents of intervention and control communities.125 The poor-quality study compared a higher-intensity CHW arm focusing on cancer control with a lower-intensity CHW arm.110–112 Although both arms demonstrated effectiveness compared with baseline values, participation in the more intense arm did not affect use of Pap smears compared with the less intense arm in the short term, but it did demonstrate effectiveness in the longer term (at 1- and 2-year followups). Followups were marked by high dropout rates, however, so the effectiveness in the longer term could be explained by selection bias.

Two high-intensity trials, one good-quality study in North Carolina,17,18 and one fair-quality study among inner-city African Americans (location unspecified),61,62 compared CHWs to mailed interventions. These two studies reported consistent results failing to demonstrate effectiveness of CHWs in improving Pap smear use compared with mailed interventions, but both studies showed that both arms demonstrated improvement compared with baseline values.

Health care utilization: mammography. Eleven studies (21 articles; Table 22), provide evidence on the effectiveness of CHW intervention with respect to breast cancer screening by mammography.15,17–22,59–62,103,104,108,110–113,116 Eight of these studies demonstrated significantly greater improvements in the CHW arm compared with the alternative (no intervention, mail, print, or minimal CHW) in either the entire sample or in subsamples.17–22,59–62,103,104,108,110–113 Two of three studies reporting nonsignificant differences between the CHW arm and the alternative were moderate-intensity, poor-quality studies comparing CHWs with no intervention;15,116 one of these studies reported nonsignificant differences between the CHW arm and the control, favoring the CHW arm. The third was a moderate-intensity fair-quality study comparing the effect of CHW interventions with controls at the community level.125 As with use of Pap smears, intensity may be a relevant analytic variable, so we report findings below first by intensity, then by study quality.

Table 22 CHW cancer screening: mammography

Author, Year Study Design Population Setting Sample Size Quality | Intensity of CHW Intervention | Study Groups | Results
Andersen, 2000^103^ RCT of communities Rural communities, Washington 6,685 Good | Low | G1: Control—no intervention reported G2: Community activities—developing social norms G3: Individual counseling—telephone G4: Community activities and individual counseling | Proportion of mammography rates among regular users (regular user is more than 1 mammogram, last mammogram within 2 years, and the previous mammogram within 2 years of the last mammogram) (self-reported): G1: 0.922 G2: 0.951, difference from G1 = 0.029, P = 0.01 (95% CI, 0.008–0.052) G3: 0.918, difference from G1 = 0.004, P = 0.81 (95% CI, −0.043-0.032) G4: 0.936, difference from G1 = 0.014, P = 0.27 (95% CI, −0.013–0.039) Proportion for G2+G3+G4: 0.935, difference from G1 = 0.013, P = 0.40 (95% CI, −0.012–0.038) In subgroup analysis, the intervention was more effective than the control in preventing relapse among women who needed >2 hours to get a medical appointment G1: 88.1%, difference in proportions for G2: 7.1% (P ≤ 0.01) G2: 6.0% (P ≤ 0.01) G3: 5.6% (P ≤ 0.05) Proportion of mammography rates among new users (under-users at baseline) (self-reported): G1: 0.578 G2: 0.599, difference from G1 = 0.021, P = 0.63 (95% CI, −0.080–0.117) G3: 0.606, difference from G1 = 0.028, P = 0.47 (95% CI, −0.064–0.113) G4: 0.604, difference from G1 = 0.026, P = 0.55 (95% CI, −0.062–0.122) Proportion for G2+G3+G4: 0.603, difference from G1 = 0.025, P = 0.40 (95% CI, −0.035–0.085) In subgroup analysis, among under-users/intervention more effective than control in increasing mammography rates among women within communities without a female physician (G2: 12.4%, G3: 10.5%, G4: 16.5%; P < 0.05) and among women with no health insurance (G2: 23.2%, G3: 9.9%, G4: 22.1%; P ≤ 0.05)
Erwin et al., 1997^108^ Prospective cohort Church or community groups, rural Mississippi River Delta region, Arkansas 412 Fair | Low | G1: Members of a Witness Project team, composed of 7 local African-American women who had survived breast or cervical cancer, spoke in groups of 2 to 5 at local churches and community organization meetings G2: Delayed intervention (control) | Ever had mammography (self-report): G1: 52.4% to 64.4% (P < 0.05 compared with baseline) G2: 60.4% to 63.3% (P = NS compared with baseline)
Sauaia et al., 2007;^59^ Welsh et al., 2005^60^ Retrospective cohort Church communities, Colorado Latina-only analysis: 4,739^59^; Latina vs. white analysis: 6,696^60^ Fair | Low | G1: Trained peer counselors (Promotoras) delivered health promotion message personally, through meetings held at least bimonthly immediately after mass and through other church events, conducted health groups that met at the home of one of the participants, same newsletter used in the printed intervention G2: Printed intervention incorporated into church display, bulletin, and/or pulpit announcements | Pretest/posttest mammography rates via ICD codes on Medicaid claims (baseline/followup): Latina-only analysis: G1: 59%/61% G2: 58%/58%, unadjusted rates not significant in either group, GEE model adjusting for insurance group, age, income, rural vs. urban, and disability found increased biennial mammograms in intervention group (P = 0.03)59 Latina vs. white analysis: G1: Latina 25%/30% (unadjusted GEE P = 0.3); non-Latina 32%/38% (unadjusted GEE P = 0.4) G2: Latina 45%/43% (unadjusted GEE P = 0.27); non-Latina 41%/44% (unadjusted GEE P = 0.02)60 Comparison of mammography rates by intervention and ethnicity, via ICD codes on Medicaid claims (pretest-posttest time-intervention interaction term by GEE) Latina: G1 vs. G2 adjusted GEE P = 0.07 Non-Latina: G1 vs. G2 adjusted GEE P = 0.10
Derose et al., 2000;^19^ Dean et al., 2000;^20^ Derose et al., 2000;^21^ Stockdale et al., 2000;^22^ Fox et al., 1998^104^ RCT Church communities, Louisiana 813 Poor | Low | G1: Control churches provided minimal intervention: a library of resource materials on cancer and cancer prevention; assistance with starting a health committee or working with an existing health committee; computer hardware, software, and a printer, as well as computer training for at least 1 church member G2: 1 session of telephone counseling annually, for 2 years, by peer counselor; counseling individualized to address barriers; churches also received computer support offered to control churches | Nonadherence rate (among baseline adherent): G1: 23.3% G2: 15.8% (P = 0.029) Nonadherence rate (among baseline nonadherent): G1: 37.4% G2: 34.8% (P = 0.324)
Earp et al., 2002^113^ Prospective cohort Black women, eastern North Carolina 801 Poor | Low | G1: Counties receiving CHW and other targeted activity—presentations to community groups and events, one-on-one conversations, use of informational/ motivational materials G2: Comparison counties—no intervention reported | Self-report of mammogram in past 2 years (baseline/followup): G1: 41%/58% G2: 56%/67% (adjusted P = 0.05) Self-report of mammogram in past 2 years, stratified by income (baseline/followup): < $12k annually—G1: 37%/59% G2: 49%/60% (adjusted P = 0.02) $12k or greater annually— G1: 56%/59% G2: 73%/82% (adjusted P = 0.92)
Dignan et al., 2005^15^ RCT Urban American-Indian women, Denver, Colorado 157 (for intervention groups, N for control NR) Poor | Moderate | G1: Control interventions NR data from Colorado Mammography Program G2: Tailored education brochure using data from baseline interview. Face-to-face planned for delivery at participant's home (1 session lasting 20–90 minutes), presenting information on breast cancer and value of early detection, review of brochure G3: Telephone intervention, as above | Mammograms over past 12 months, self-report (baseline/followup): G1: 51.9%/50.0% G2: 29%/41.8% G3: 34.4%/45.2% Chi-square: G1 vs. G2+G3: 2.68, P = 0.10; P for G2 vs. G3: 0.83; P for G2, pre-changes: 0.029; P for G3, pre-changes: 0.197
Hiatt et al., 2008^125^ Prospective cohort Public health clinics and the low-income neighborhoods in San Francisco and Contra Costa County, California 1,616 Fair | Moderate | G1: One-on-one visits at various events and locations; presentations to community-based organizations (agencies); and Women’s Health Days, offering free mammograms, Pap tests, and breast self-examination instruction G2: No intervention (control) | Ever completed mammography (logistic regression, 95% CI) Residence in outreach area over time: 0.7 (0.5–1.0) Completed mammography in past 2 years (logistic regression, 95% CI) Residence in outreach area over time: 0.7 (0.5–1.0) Completed 3 mammographies in past 5 years (logistic regression, 95% CI) Residence in outreach area over time: 0.8 (0.5–1.1)
Navarro et al., 1998;^111^ Navarro et al., 1995;^110^ Navarro et al., 2000^112^ RCT Low-income Latinas, southeast San Diego County, California 365 Poor | Moderate | G1: CHW delivering community living skills sessions, details NR G2: CHW delivering cancer education sessions, 12 weekly group sessions conducted over 3 months plus 2 additional sessions offered within a year of beginning of group meetings | Pretest-posttest changes in percentage of women ≥40 years who had mammogram within past year: Participant unit of analysis (n = 113) G1: 7 G2: 21.4 P = 0.029 t = 2.22 CHW unit of analysis (n = 33) G1: 6.8 G2: 24.3 P = 0.063 t = 1.96 Odds of mammogram 1-year and 2-year followup for cancer screening group (P value): Year 1: 1.50 (0.484) Year 2: 3.88 (0.018)
Wilson et al., 2008^116^ Repeated cross-sectional survey of women attending salons randomly assigned to experimental and control groups Neighborhood hair salons, Brooklyn, New York 40 salons/1,210 respondents Poor | Moderate | Intervention consisted of education, counseling, and information on location of screening services during salon appointment G1: Control, before intervention G2: Stylist group, before intervention G3: Control, after intervention G4: Stylist group, after intervention | Mammogram in past 3 months: G1: 13% G2: 14% AOR, 1.1 (95% CI, 0.8–1.7)
Paskett et al., 2006;^17^ Katz et al., 2007^18^ RCT Community health centers, Robeson County, North Carolina 820 Good | High | G1: Sent control letter and NCI brochure about the need for regular cervical cancer screening 6 months after random assignment, followed by letter and NCI brochure about the need for mammography 3 months after followup assessment G2: Individualized health education program that was culturally acceptable and tailored to meet the needs of each woman, intensive face-to-face interactive educational program administered over a 9-to 12-month period, consisting of 3 in-person visits, with educational materials provided each visit and followup telephone calls and mailings after | Mammogram receipt from medical record data: G1: 27.3% G2: 42.5%, RR, 1.56; 95% CI, 1.29–1.87, P <.001 Significant differences within racial groups as well
Sung et al., 1997;^61^ Sung et al., 1992^62^ RCT Inner-city African Americans, state unspecified 195 Fair | High | G1: CHW home visits, education on breast and cervical cancer, breast self-exam, educational materials on screening, facilitation to address logistical barriers to screening G2: Mailed educational materials on cancer screening | Pretest/posttest change in self-report of receiving mammography for entire sample: G1: 35.5%/50.4% G2: 34.3%/39.4%, difference in change: 9.8% (95% CI, 2.9–16.7) Pretest/posttest change in self-report of receiving mammography, postintervention respondents only: G1: 32.5%/58.7% G2: 34.0%/47.9%, difference in change: 12.4% (95% CI, 1.0–24.3) Posttest rate of self-report of receiving mammography, women not previously on recommended screening schedules, whole sample: G1: 29.7% G2: 24.4%, difference in change: 5.8% (95% CI, −7.0–18.6) Posttest rate of self-report of receiving mammography, women not previously on recommended screening schedules, postintervention respondents only: G1: 50.0% G2: 35.5%, difference in change: 14.5% (95% CI, 4.5–23.6)

CHW, community health worker; CI, confidence interval; G, group; GEE, generalized estimating equation; ICD, International Classification of Diseases; N, number; NCI, National Cancer Institute; NR, not reported; NS, not significant; OR, odds ratio; RCT, randomized controlled trial; RR, relative risk; t, t-test.

Four studies did not report changes over time;15,17–22,103,104 one study failed to show improvement in the intervention area,125 and the remaining six studies all demonstrated some improvement in the control arm (no intervention, delayed intervention, mail, print, or minimal CHW), although the improvement was not statistically significant.

Studies conducting subgroup analyses demonstrated that CHW interventions can provide benefits for subpopulations. Four studies provide evidence that CHW interventions are likely to be more beneficial than alternative interventions in low-income, minority populations with some health care barriers.19–22,60,103,104,113

Low-intensity interventions generally compared CHW with minimal to no intervention, We identified five such studies, one good-quality,103 two fair,59,60,108 and two poor.19–22,104,113 Collectively CHWs were generally effective in raising mammography rates, but with potentially greater effects in subpopulations.

The good study from Washington State, comparing a no-intervention control group with CHW groups receiving community activities, individual counseling, or a combination of community activities and individual counseling found that all the CHW intervention arms had higher rates of new users than the no-intervention control, but the study did not find significantly greater effectiveness of CHW arms in comparison with a no-intervention control.103 The community activities arm appeared to be more effective than a no-intervention control in preventing relapse (that is, in ensuring that regular users or women who were adherent to recommended screening guidelines at baseline continued to be adherent at followup) than in enrolling new users.

One fair-quality study involved Latinas in Colorado enrolled in Medicare or Medicaid fee-for-service, or three other health maintenance organizations (Kaiser Permanente of Colorado, Access, and Anthem Blue Cross and Blue Shield).59 It found nonsignificant and modest differences in mammography screening rates in unadjusted analyses that compared a CHW intervention with a printed intervention. In adjusted analysis, the difference between the two arms was statistically significant, favoring the CHW arm. The other fair-quality study, in Arkansas, also reported significantly greater improvements in self-reported use of mammography in the CHW arm compared with a delayed intervention arm. However, the two groups differed significantly at baseline, with higher rates of ever-use of mammography reported in the control group; thus a ceiling effect limiting improvements in the control group cannot be ruled out.108

The two poor-quality, low-intensity studies also suggested favorable results for the CHW arm compared with a minimal19–22,104 or no-intervention arm113 for the entire sample or for subpopulations.

Four moderate-intensity interventions, one of fair quality125 and three of poor quality,15,110–112,116 reported outcomes for self-reported mammography use. The fair-quality study in San Francisco and Contra Costa found no statistically significant difference in changes in self-reported mammography between intervention communities and control communities.125 One study in New York, which compared CHW with no-intervention controls, found no significant differences between intervention and control arms after the intervention in use of mammography during the prior 3 months.116 Both studies described measure effects at the community level rather than at the individual level. Low penetration of the intervention and potential contamination between experimental and control samples limit the interpretation of the results.

Two other studies, both assessed as moderate intensity overall, compared higher-intensity CHW to lower-intensity CHW intervention;15,110–112 they both reported improvements in both arms. Only the study in San Diego County, California, found significant differences; it demonstrated that the relatively more intense arm was more effective in the 3-to 6-month period following the intervention.110–112 These improvements were not consistently significantly different between the two arms over the long run (1-and 2-year followups) for a reduced and potentially self-selected subsample.

Two high-intensity trials, one good-quality17,18 and one fair-quality,61,62 both compared CHWs to mailed interventions and reported improvements in the CHW arms of their studies. Only the good-quality study (using Medicaid records from North Carolina) found significant differences in mammography rates between the CHW arm and the mailed intervention arm.17,18 The fair-quality study, using self-reported mammography among inner-city African Americans (location unspecified), did not find any significant differences for the overall sample using intention-to-treat analysis, but it did report significant differences when analysis was limited to a potentially biased subsample of respondents available at followup.62,129

Four studies found evidence of effect modification in subgroup analysis.19–22,60,103,104,113 The evidence is derived from low-intensity studies of varying quality. The good-quality study from Washington found that CHW intervention arms were more effective than a control arm in subgroups: among regular users (women adherent at baseline), the CHW intervention arms showed significantly greater rates of mammography use among women who needed less than 2 hours to schedule a medical appointment.103 In the same study, subgroup analysis for under-users (women who were not adherent at baseline) found that the CHW interventions were significantly more effective than the no-intervention control among women without female doctors or insurance. These subgroup findings suggest that the CHW approach is effective in addressing some, but not all, access barriers to the use of mammography.

The fair-quality study from Colorado59,60 reported weak but slightly more powerful effects of the CHW approach compared with a printed intervention approach in increasing mammography rates among Medicaid-enrolled Latinas compared with non-Latina whites (P = 0.07 for Latinas, and P = 0.10 for non-Latina whites).60 Similarly, the poor-quality studies also suggested subgroup effects. One study found CHWs to be more effective than a no-intervention control group in increasing rates of self-reported mammography for the overall sample and in groups with incomes below $12,000, but not in groups with incomes equal to or exceeding $12,000.^113^ Another found that the CHW approach was more effective than with a minimal intervention approach in ensuring conversion to adherence among under-users rather than in maintaining adherence among regular or adherent users.19–22,104

Health care utilization: clinical breast examination. Four studies reporting on clinical breast examination (seven articles; Table 23)61,62,110–112,116 included a high-intensity and three moderate-intensity interventions. Two of these studies were of fair quality;61,62,125 the other two were rated poor.110–112,116 Together the studies suggest that CHW interventions are not effective in comparison with other alternatives, although two studies that provide information on changes between baseline and followup found that the CHW arm results in improvements over time.

Table 23 CHW cancer screening: clinical breast examination

Author, Year Study Design Population Setting Sample Size Quality | Intensity of CHW Intervention | Study Groups | Results
Sung et al., 1997^61^; Sung et al., 1992^62^ RCT Inner-city African Americans, state unspecified 195 Fair | High | G1: CHW home visits, education on breast and cervical cancer, breast self-exam, educational materials on screening, facilitation to address logistical barriers to screening G2: Mailed educational materials on cancer screening | Pretest/posttest change in self-report of receiving CBE for entire sample: G1: 55.2%/64.5% G2: 55.7%/59.5%, difference in change: 4.9 (95% CI, −6.1–4.1) Pretest/posttest change in self-report of receiving CBE, postintervention respondents only: G1: 59.1%/72.0% G2: 57.8%/61.8%, difference in change: 8.9% (95% CI, 1.1–16.7) Posttest rate of self-report of receiving CBE, women not previously on recommended screening schedules, whole sample: G1: 37.0% G2: 28.6%, difference in change: 8.4% (95% CI, −6.9–23.7) Posttest rate of self-report of receiving CBE, women not previously on recommended screening schedules, postintervention respondents only: G1: 71.1% G2: 46.5%, difference in change: 24.6% (95% CI, 3.9–45.3)
Hiatt et al., 2008^125^ Prospective cohort Public health clinics and the low-income neighborhoods in San Francisco and Contra Costa County, California 1,616 Fair | Moderate | G1: One-on-one visits at various events and locations; presentations to community-based organizations (agencies); and Women’s Health Days, offering free mammograms, Pap tests, and breast self-examination instruction G2: No intervention (control) | Ever completed clinical breast examination (Total N [%] pretest/Total N [%] posttest): G1: 801 (94)/812 (95) Χ ^2^ = NR, not significant G2: 798 (82)/803 (87) Χ ^2^ = NR, P=0.006 Completed clinical breast examination in past year (Total N [%] pretest/Total N [%]posttest): G1: 800 (75)/809 (74) Χ ^2^ = NR, not significant G2: 796 (56)/803 (60) Χ ^2^ = NR, not significant Completed 3 or more clinical breast examinations in past 5 years (Total N [%]pretest/Total N [%] posttest): G1: 793 (73)/809 (73) Χ ^2^ = NR, not significant G2: 792 (54)/800 (54) Χ ^2^ = NR, not significant
Navarro et al., 1998;^111^ Navarro et al., 1995;^110^ Navarro et al., 2000^112^ RCT Low-income Latinas, southeast San Diego County, California 365 Poor | Moderate | G1: CHW delivering community living skills sessions, details NR G2: CHW delivering cancer education sessions, 12 weekly group sessions conducted over 3 months plus 2 additional sessions offered within a year of beginning of group meetings | Pretest-posttest changes in percentage of women who had CBE within past year: Participant unit of analysis (n = 359) G1: 15.5 G2: 17.7 P = 0.589 t = 0.54 CHW unit of analysis (n = 35) G1: 19.3 G2: 19.5 P = 0.967 t = 0.04 Odds of CBE 1-year and 2-year followup for cancer screening group (P value): Year 1: 1.21 (0.556) Year 2: 1.93 (0.038)
Wilson et al., 2008^116^ Repeated cross-sectional survey of women attending salons randomly assigned to experimental and control groups Neighborhood hair salons, Brooklyn, New York 40 salons/1,210 respondents Poor | Moderate | Intervention consisted of education, counseling, and information on location of screening services during salon appointment G1: Control, before intervention G2: Stylist group, before intervention G3: Control, after intervention G4: Stylist group, after intervention | CBE in past 3 months: G1: 27% G2: 27%, P = 0.85 for differences between G1 and G2 G3: 27% G4: 29% AOR, 1.2; adjusted 95% CI, 0.9–1.7

Adj, adjusted; CBE, clinical breast examination; CHW, community health worker; CI, confidence interval; NR, not reported; OR, odds ratio; RCT, randomized controlled trial; t, t-test.

The fair-quality high-intensity trial found no differences between the CHW arm and a mailed intervention, with the exception of a reduced and possibly selective sample of respondents only at followup.61,62 The fair-quality moderate-intensity study found no difference over time in most measures of self-reported clinical breast examination in intervention communities or control communities.125 Of the two poor-quality moderate-intensity studies, one trial compared a more intense CHW arm with a less intense CHW arm110–112 and the cross-sectional study compared it with a no-intervention arm.116 Neither study reported significant differences, although the women in the more intense CHW arm of the trial did report higher rates of clinical breast examination after the intervention.

Health care utilization: colorectal cancer screening. Two studies, one of moderate intensity and fair quality, and another of low intensity and poor quality compared three groups on outcomes for fecal occult blood tests (FOBT) and other colorectal cancer screening tests (Table 24).107 In the fair-quality moderate-intensity intervention, patients who received navigation services had higher rates of FOBT after three months of services than patients who received usual care, but these differences were not statistically significant. Patients receiving navigation services were significantly more likely than controls to have set an endoscopy appointment at three months and kept it by six months after the intervention.106 The low-intensity poor-quality study reported that rates of FOBT were higher in the CHW arm over time; however, the CHW arm and the comparison arms of a no-intervention control or of tailored print and videotapes did not differ significantly. The study reported no benefit of the intervention for other colorectal screening tests.

Table 24 CHW cancer screening: colorectal cancer screening

Author, Year Study Design Population Setting Sample Size Quality | Intensity of CHW Intervention | Study Groups | Results
Jandorf et al., 2005 RCT East Harlem, New York City 78 Fair | Moderate | G1: Patient navigator (education and assistance with screening and navigation process) G2: Usual care | Completed FOBT after 3 months (%):G1: 42.1 G2: 25.0 P = 0.086 Had endoscopy appointment at 3 months (%):G1: 18.4 G2: 0 P = 0.005 Completed endoscopy at 3 months (%):G1: 15.8 G2: 5.0 P = 0.115 Completed endoscopy at 6 months (%):G1: 23.7 G2: 5.0 P = 0.019
Campbell, 2004^107^ RCT African-American rural churches, North Carolina NR (12 churches; completers/dropouts of individual participants from each church NR) Poor | Low | G1: Control churches were offered health education sessions and speakers on topics of their choice not directly related to study objectives G2: Organized and conducted at least 3 church-wide activities on spreading information and enhancing support for healthy lifestyle and CRC screening (LHA) G3: 4 personalized computer-tailored newsletters and 4 targeted videotapes corresponding to the same behaviors mailed to participants’ homes bimonthly for first 6 months after baseline data collection; 4th targeted videotape mailing was 9 months after baseline G4: LHA and targeted videotapes | FOBT test in past year (% baseline/% followup): G1: 30.4%/21.7% G2: 23.5%/33.3% G3: 19.7%/36.8% G4: 19.5%/31.0% P = 0.08 Other CRC test in past year (% baseline/% followup): G1: 20.3%/27.5% G2: 19.6%/25.5% G3: 23.7%/21.1% G4: 26.4%/14.9% P = ns

CRC, colorectal cancer; FOBT, fecal occult blood test; LHA, lay health advisor; NR, not reported; ns, not significant; RCT, randomized controlled trial.

### Outcomes for Chronic Disease Management

Chronic disease management: diabetes mellitus. Study characteristics. Four studies (eight articles; Table 25), three RCTs,27,88–92,124 and one prospective cohort study93 examined outcomes of CHW interventions for diabetes care among underserved minority populations with type 2 diabetes mellitus. All studies were rated fair quality. Three studies27,88–93 used a high-intensity intervention; one study124 used a moderate-intensity intervention.

Table 25 CHW chronic disease management: diabetes mellitus

Author, Year Study Design Population Setting Sample Size Quality | Intensity of CHW Intervention | Study Groups | Results
Beckham, 2008^93^ Cohort Health center for underserved with type 2 diabetes Hawaii N: 116 Fair | High | G1: Diabetes case management by CHW, including home visits, based on needs of patients; CHWs collaborate with multidisciplinary team to determine high-priority learning areas and develop an intervention plan to implement during subsequent visits, plan included a blood regimen and target levels, diet plan, exercise plan, medication schedule, insulin injection plan, and preventive health/health maintenance plan G2: Usual care with multidisciplinary team approach, minus CHW; glucose self-monitoring | HgbA1c, mean change from baseline (SD): G1: −2.2 (1.8) G2: −0.2 (1.5) P < 0.0001* *Note on P value: the investigators did not report a value comparing the groups; RTI researchers calculated the value using the data in the article
Corkery, 1997^124^ RCT Hispanic and African-American populations in East Harlem, New York City, New York N: 64 Fair | Moderate | G1: Intervention—CHW acted as liaison, attended clinic sessions, interpreted, reinforced self-care instructions and appointment reminders G2: Encounters occurred between nurse and patient only (control) | Diabetes education program completion: G1: 80% G2: 47% (P = 0.01) No difference in mean change in HgbA1c between groups
Gary 2000;^91^ Batts 2001;^88^ Gary 2003;^89^ Vetter 2004;^92^ Gary 2005^90^ RCT Project Sugar African-American population in East Baltimore, Maryland N: 186 Fair | High | G1: Usual care—continued on-going care from their own health professionals plus quarterly newsletter containing information on diabetes-related health topics G2: NCM intervention—RN + certified diabetes educator, 45-minute face-to-face clinic visits and/or telephone contacts, direct patient care, management, education, counseling, followup, referral, physician feedback— goal was 3 visits per year G3: CHW intervention—45 to 60-minute face-to-face home visits and/or telephone contacts, no direct implementation of therapeutic strategies but facilitated preventive care by offering to schedule appointments and provide education, 3 visits per year G4: Combined NCM plus CHW—3 visits per year with each | HgbA1c, mean change from baseline at 2 years: G1: ref G2: −0.31 ± 0.49% G3: −0.30 ± 0.48% G4: 0.8 ± 0.52% (P < 0.05 for within-group change from baseline for G4 only) LDL, mean change from baseline at 2 years: G1: −16.7± 5.5 mg/dl G2: +6 (approximate) (P < 0.05 for within-group change from baseline) G3: +6 (approximate) G4: +4 (approximate) (P < 0.05 for within-group change from baseline) SBP, mean change from baseline at 2 years: G1: ref G2: +6 (approximate) (P < 0.05 for within-group change from baseline) G3: −4 (approximate) G4: −2 (approximate) Dietary risk scores—validated, mean change from baseline at 2 years: G1: ref G2: −2.4 ± 1.99 G3: −3.45 ± 1.87 G4: −2.13 ± 1.92
Lujan, 2007^27^ RCT Mexican Americans in a major border city in Texas N: 150 Fair | High | G1: A team of 2 promotoras delivered 8 weekly, 2-hour participative group classes and followup to intervention group, using multiple audiovisual teaching aids and handouts, contacted class participants by telephone biweekly to answer questions, reinforce education, promoted behavior change, sent postcards biweekly G2: Usual care by clinic staff—verbal information and 1 or 2 pamphlets on diabetes self-management | HgbA1c at baseline (SD)/6 months (SD): G1: 8.21 (2.2)/7.76 (1.87) G2: 7.71 (1.49)/8.01 (1.8) Mean change between groups: P < 0.001 Bilingual Diabetes Knowledge Questionnaire (validated): baseline (SD)/6 months (SD): G1: 69.1 (13.6)/77.2 (14.4) G2: 66.9 (15.2)/65.1 (21.0) Mean change between groups: P <.002 Diabetes Health Belief Measure–(validated): baseline (SD)/6 months (SD): G1: 56.4 (12.2)/54.6 (8.4) G2: 57.0 (10.6)/50.8 (13.6) Mean change between groups: P < 0.01

Approx, approximately; CHW, Community Health Worker; DKQ, Diabetes Knowledge Questionnaire; HgbA1c, Hemoglobin A1c; LDL, low-density lipoprotein; NCM, nurse case manager; RCT, randomized controlled trial; RN, Registered nurse; SBP, systolic blood pressure.

The 6-month RCT conducted in Texas used a high-intensity intervention for Mexican Americans that compared eight weekly, 2-hour group classes with promotoras to usual care plus educational pamphlets.27 The RCT in New York City used a moderate-intensity intervention for inner-city Hispanics and African Americans that evaluated the use of CHWs as clinic liaisons compared with nurse-patient encounters.124 The Project Sugar trial RCT in Baltimore, Maryland, compared several high-intensity interventions in inner-city African Americans with type 2 diabetes: (1) CHW face-to-face home visits and telephone contact, (2) nurse care manager intervention, (3) a combined nurse care manager and CHW, and (4) standard clinical care with an additional quarterly diabetes newsletter.88–92 The prospective cohort study in Hawaii examined a high-intensity intervention comparing CHW diabetes case management, including home visits, in addition to a multidisciplinary team, with usual clinical care involving a multidisciplinary team approach.93 Heterogeneity of population, study designs, interventions, and outcomes preclude quantitative synthesis of results.

Overview of results. Of these four studies on diabetes management, two studies found the CHW intervention to be beneficial in decreasing hemoglobin A1c (HgbA1c) as compared with usual care;27,93 conversely, two studies found no difference between groups in mean change from baseline in HgbA1c.88–92,124 The Texas study also evaluated outcomes of knowledge and found that the CHW intervention was effective compared with usual clinical care in increasing diabetes knowledge.27 The Hawaii study found that diabetes case management by a CHW in conjunction with a multidisciplinary team was more effective at decreasing HgbA1c than a multidisciplinary team alone.93 The New York study demonstrated that a CHW liaison was more effective than usual clinical care in behavioral changes leading to program completion rates.124 Project Sugar, a high-intensity study, found significant changes from baseline within, but not between, groups for various health outcomes.88–92

Knowledge. The Texas study evaluated outcomes for improved knowledge at 6 months in diabetic patients following eight weekly CHW-led group classes in Mexican Americans.27 A validated tool, the bilingual Diabetes Knowledge Questionnaire (DKQ), showed a difference between arms, with an improved score in the CHW group compared with the group receiving usual care plus educational pamphlets (P < 0.002).27

Behavior. Project Sugar evaluated dietary risk scores (which identifies positive as well as problematic dietary behaviors and measures potential barriers to dietary change). Scores improved across all CHW arms as compared with the usual clinical care group following a high-intensity CHW intervention (all CHW arms versus usual clinical care [score ± standard deviation]: −2.4 ± 1.99 versus −3.45 ± 1.87 versus −2.13 ± 1.92; P not reported).88–92 The New York study demonstrated an increased proportion of completion of a diabetes education program after a low-intensity CHW intervention compared with usual clinical care (80 percent versus 47 percent, P = 0.01).124

Satisfaction. No study reported outcomes about satisfaction with diabetes care.

Health outcomes. The Texas trial demonstrated better improvement in diabetes control (measured by mean change in HgbA1c) in the high-intensity CHW intervention group than in the usual care group after 6 months (P < 0.001).27 The Hawaii study found that a high-intensity CHW intervention in conjunction with a multidisciplinary team was more effective in decreasing mean HgbA1c when compared with usual care with a multidisciplinary team (−2.2 versus 0.2).93 The Hawaii study investigators did not report P value comparing the groups; we were able to calculate it using the data provided in the article and found the difference to be statistically significant (P < 0.0001).93 Project Sugar reported no significant change between the four study groups for the primary outcome, HgbA1c. The only group with a significant improvement from baseline to 2 years was the CHW plus nurse care manager arm (improvement of 0.8 percent ± 0.52 percent, P < 0.05).88–92 Postintervention, a power calculation showed the study was powered to detect a difference of only 1.2 percent change in HgbA1c. Secondary outcomes from Project Sugar included low density lipoprotein (LDL) cholesterol, systolic blood pressure, and diastolic blood pressure; none differed significantly between study groups in change from baseline measures. LDL cholesterol changed for the worse within the CHW plus nurse care manager arm (+4 mg/dl, P < 0.05).88–92

Health care utilization. No study evaluated diabetes care utilization.

Chronic disease management: hypertension. Study characteristics. Four studies (five articles; Table 26), two RCTs23,98,99 and two prospective cohorts,94,95,123 examined outcomes of moderate-intensity CHW interventions for blood pressure management among adult patients with hypertension. We rated one study as fair quality and three as poor quality. All four studies evaluated a CHW intervention compared with an intervention that involved a CHW in a lesser capacity.23,94,95,98,99,123 The two RCTs, one fair98 and one poor99 quality, evaluated CHW interventions in inner-city minority populations.23,98,99

Table 26 CHW chronic disease management: hypertension

Author, Year Study Design Population Setting Sample Size Quality | Intensity of CHW Intervention | Study Groups | Results
Levine, 2003^98^ RCT African Americans in inner-city Baltimore, Maryland N: 789 Fair | High | G1: G2 care plus 5 CHW visits with blood pressure measurement, addressing issues of blood pressure management and access to medical care G2: CHW home visit for education, counseling, and referral | Pre/postintervention blood pressure (systolic/diastolic): G1: 147.7/89.2 (95% CI, 145.5–149.9/87.8–90.6) → 145/86.2 (95% CI, 142.3–147.7/84.2–88.2) G2: 148.6/89.3 (95% CI, 146.4–150.7/87.8–90.8) → 142.1/84.7 (95% CI, 138.8–145.4/82.7–86.7) P < 0.05 for differences between baseline and followup for each group, P > 0.1 between groups Percentage with adequate hypertension control (< 140/90): G1: 16% → 36% G2: 18% → 34% pre/post P <0.01 group difference NS
Ward, 2000;^99^; Morisky, 2002^23^ RCT Inner-city African Americans and Hispanics in a large West Coast city N: 1,367 Poor | Moderate | G1: CHW post-clinic appointment counseling session G2: Appointment reminder cards and telephone calls G3: Home visits by CHW G4: Standard clinic care | Percentage with blood pressure control (< 140/90)—baseline/6 months/12 months: G1: 35.2%/46%/46% (P < 0.01) G2: 40.2%/42%/48% (P < 0.01) G3: 29.7%/NR but “improved” G4: 36.9%/NR but “improved” All groups improved; differences between groups NR
Frate, 1983^95^ Frate,1985^94^ Prospective cohort Rural central Mississippi N: 667 Poor | High | G1: Hypertension health counselors—monthly visits that encouraged compliance to both pharmacological and nonpharmacological therapy that had been prescribed G2: Family-based self-help G3: Church-based self-help | Proportion of hypertensives controlled (< 160/95): G1: 80.6% G2: 90.0% G3: 79.9% (P < 0.0001)
Bone, 1989^123^ Prospective cohort Low-income African Americans in emergency department in Baltimore, Maryland N: 722 Poor | Moderate | G1: Control (not able to be contacted by CHW) G2: Contacted by CHW; initially, all patients contacted by CHWs in emergency department; CHWs measured pulse and blood pressure, provided educational counseling, identified barriers related to referrals, assisted with appointment-keeping and adherence to treatment plan; session lasted about 20 minutes | Returned to emergency department for followup appointment: G1: 41% G2: 60% (P < 0.001)

CHW, community health worker; NS, not significant; RCT, randomized controlled trial.

The fair-quality trial from Baltimore, Maryland, evaluated a CHW home visit for patient education, counseling, and referral compared with a CHW home visit plus five additional visits for blood pressure measurement and management, and access to medical care.98 The poor-quality RCT from the West Coast, rated as such because of a high attrition rate, use of a completers analysis, and high potential for bias, evaluated CHW postclinic appointment counseling sessions, CHW home visits, appointment reminder cards and calls, and standard clinical care.23,99

The prospective cohort study from rural central Mississippi, which we rated as poor quality because of a high potential for confounding and inappropriate statistical methods, evaluated a moderate-intensity CHW intervention using CHWs as “hypertension health counselors” in providing monthly visits encouraging compliance with previously prescribed pharmacological and nonpharmacological therapies.94,95 The other prospective cohort study from Baltimore, Maryland, which we rated poor because of a lack of methods describing an analysis plan a priori, a high potential for confounding, and lack of comparison of participant characteristics at baseline, evaluated a moderate-intensity CHW intervention..123 It examined the impact on appointment followup of a CHW followup telephone call after an emergency department visit during which patients had their blood pressure measured, were provided education counseling, and were assisted with appointment keeping and adherence to a treatment plan. The comparison group included patients who had received a single CHW visit in the emergency department but who could not be reached later for assistance in appointment keeping.123 Heterogeneity of study designs, interventions, and outcomes preclude quantitative synthesis of results.

Overview of results. We did not find any fair- or good-quality studies that compared the impact of a CHW intervention with usual care on blood pressure control. Of the three studies that evaluated blood pressure control, only the Mississippi prospective cohort demonstrated a significant difference between study groups in terms of proportion of hypertensive subjects controlled (defined in this study as blood pressure less than 160/95).94,95 Neither RCT demonstrated between-group differences in blood pressure control.23,98,99 However, these studies did note improvement from baseline to study completion within all groups, some of which were statistically significant.23,98,99 The Baltimore prospective cohort did not evaluate blood pressure control but instead examined health care utilization.123 This study demonstrated that CHW worker followup was more effective than no followup in increasing return visit appointment rates.

Knowledge. No study reported improved knowledge.

Behavior. No study reported improved behaviors.

Satisfaction. No study reported satisfaction outcomes.

Health outcomes. We did not find any fair- or good-quality studies that compared the impact of a CHW intervention with usual care on blood pressure control. Three of the four studies did report on blood pressure control. Both RCTs found an improvement within most groups but no difference between groups in terms of blood pressure control.23,98,99 The fair-quality RCT demonstrated that the low-intensity CHW arm (1 home visit) and the high-intensity CHW arm (6 home visits) both improved blood pressure control. However, the difference between the groups was not statistically significant.98 The poor-quality RCT also demonstrated an improvement in blood pressure within all groups, including the usual care arm, but no significant difference between groups.23,99 The Mississippi prospective cohort study did not report statistical tests for either between- or within-group comparisons.94

Health care utilization. The poor-quality prospective cohort in a Baltimore emergency department demonstrated that patients in the low-intensity CHW intervention were more likely to return for a followup appointment than were patients in the comparison group (60 percent versus 40 percent, P < 0.001).123 However, the comparison patients were not able to be contacted for followup by the CHW, thus biasing the results for this outcome in favor of the intervention arm.123

Chronic disease management: infectious diseases. Study characteristics. One RCT of fair quality examined outcomes of a CHW intervention to facilitate access to health care for tuberculosis (TB) in a homeless population with positive purified protein derivative (PPD) test results in San Francisco, California (Table 27).122 This study used a moderate-intensity model. CHWs who were familiar with homelessness were assigned to TB-infected individuals and responsible for accompanying them to their clinic appointments.122 Outcomes were compared with outcomes for a group receiving a monetary incentive to attend the TB clinic in addition to an appointment and bus tokens and with a control group who were given clinic appointments and bus tokens.

Table 27 CHW chronic disease management: infectious diseases

Author, Year Study Design Population Setting Sample Size Quality | Intensity of CHW Intervention | Study Groups | Results
Pilote, 1996^122^ RCT Homeless people with positive purified protein deriviative for tuberculosis in San Francisco, California N = 244 Fair | Moderate | G1: Peer health advisor—met with patient and took them to clinic appointment, facilitated paperwork, reviewed physician recommendations G2: Monetary incentive—$5 at clinic, appointment, and bus tokens G3: Usual care—appointment and bus tokens | Adherence to first followup appointment (95% CI): P calculated vs. G3 G1: 75% (70–80); (P = 0.004) G2: 84% (76–92); (P < 0.001) G3: 53% (47–59)

CI, confidence interval; RCT, randomized controlled trial.

Overview of results. This RCT demonstrated that a CHW intervention was less effective than the monetary incentive but more effective than usual care in leading to adherence to a first followup appointment.122

Knowledge. This RCT did not report outcomes for improved knowledge.

Behavior. This RCT did not report outcomes for improved behaviors.

Satisfaction. This RCT did not report outcomes of satisfaction.

Health outcomes. This RCT did not report outcomes of health.

Health care utilization. A moderate-intensity CHW intervention was less effective than a monetary incentive ($5) in increasing adherence to a first followup clinic appointment (75 percent [95% CI, 70–80] versus 84 percent [95% CI, 76–92], P = not reported). However, the CHW intervention was more effective than a control group who received an appointment and bus tokens (75 percent [95% CI, 70–80] versus 53 percent [95% CI, 47–59], P = 0.004).122

Chronic disease management: back pain. Study characteristics. One RCT of fair quality evaluated a moderate-intensity intervention of four 2-hour weekly group classes led by CHWs compared with usual care supplemented by a book on back pain (Table 28).114 The classes focused on applying problem-solving techniques for back pain self-management and included educational materials (book and videos) supporting active management of back pain.114

Table 28 CHW chronic disease management: back pain

Author, Year Study Design Population Setting Sample Size Quality | Intensity of CHW Intervention | Study Groups | Results
Von Korff, 1998^114^ RCT People with chronic back pain in Washington state N = 255 Fair | Moderate | G1: 4, 2-hour classes held once a week, with 10 to 15 participants, led by 2 CHWs G2: Usual care includes back pain book | "The next time I have back or leg pain, I will try to manage the problem without seeing a health professional" (not validated): G1: 77% agreed G2: 60% agreed (P = 0.008) 50% or greater reduction in Roland Disability Questionnaire Score from baseline at 6 months (validated): G1: 47.9% G2: 33% (P = 0.02) Roland Disability at 12 months (validated): G1: 5.75 (6.31) G2: 6.75 (6.39) (P = 0.092) Worry rating (0–10) at 12 months (not validated): G1: 2.63 (2.58) G2: 3.83 (3.08) (P = 0.013)

CHW, community health worker; RCT, randomized controlled trial.

Overview of results. This fair-quality RCT found that a moderate-intensity CHW intervention was significantly effective in reducing back pain when compared with a control group at 6 months; the groups did not differ significantly at 12 months.114

Knowledge. This RCT did not report outcomes for improved knowledge.

Behavior. This RCT did not report changes in participant behavior.

Satisfaction. This RCT did not report outcomes of satisfaction.

Health outcomes. The moderate-intensity CHW intervention was more effective in decreasing participant back pain than usual care supplemented by a book on back pain at 6 months.114 More participants in the intervention arm achieved a 50 percent or greater reduction in Roland Disability Score from baseline than in the control group at 6 months (47.9 percent versus 33 percent, P = 0.02).114 However, Roland Disability Scores at 12 months did not differ between arms (5.75 ± 6.31 versus 6.75 ±6.39, P = 0.092).114 The authors attributed this lack of difference to the fact that the intervention was intended not to reduce pain intensity but rather to lower patient worries about back pain.114 Additionally, participants receiving a CHW intervention had a lower worry rating (unvalidated tool) than those in the control group at 12 months (2.63 ± 2.58 versus 3.83 ± 3.08, P = 0.013).114

Health care utilization. This RCT did not report on health care utilization.

Other. Participants in the CHW arm reported being more likely to self-manage back or leg pain than those in the control arm, a measure of self-efficacy (77 percent versus 60 percent, P = 0.008).114

Chronic disease management: mental health. Study characteristics. One RCT of poor quality with three trial arms evaluated an assertive community treatment with a CHW intervention compared with an assertive community treatment alone and with a brokered case management intervention (Table 29).120,121 The study population included people in St. Louis, Missouri, who were homeless or at risk for being homeless and were diagnosed with serious psychiatric diagnoses.120,121 The CHWs’ role was to assist with daily living and be available for leisure activities. This intervention was rated as high-intensity as defined in KQ 1. A high rate of attrition (only 85 of 165 provided followup) contributed to the poor-quality rating of this study.120,121

Table 29 CHW chronic disease management: mental health

Author, Year Study Design Population Setting Sample Size Quality | Intensity of CHW Intervention | Study Groups | Results
Wolff, 1997^121^ Morse, 1997^120^ RCT Homeless with serious psychiatric conditions in St. Louis, Missouri N = 165 Poor | High | G1: Assertive community treatment— intensive individualized treatment, responsibility for providing or coordinating all services needed by client, persistent followup and in-person service delivery, performed by staff with backgrounds in psychology, social work, and counseling G2: G1 plus CHW, whose role was to assist with activities of daily living and be available for leisure activities G3: Brokered case management | Number of days in stable housing in past month—baseline (SD)/18 months (SD): G1: 6.36 (11.71)/21.75 (12.76) G2: 4.94 (11.08)/17.54 (14.45) G3: 7.18 (12.38)/16.00 (14.86) (P < 0.31) Client satisfaction (validated): G1: 3.27 (0.42) G2: 3.12 (0.57) G3: 2.74 (0.68) P < 0.01 Brief Psychiatric Rating Scale Total Symptom Score (validated): G1: 53.54 (15.54)/39.96 (12.25) G2: 57.97 (20.29)/38.77 (12.23) G3: 50.6 (14/31)/51.6 (16.7) P = 0.001 Program contact (days/month): G1: 8.29 (7.51) G2: 6.95 (4.91) G3: 0.3 (0.49) P < 0.001

CHW: community health worker; RCT, randomized controlled trial; SD: standard deviation.

Overview of results. Clients in the assertive community treatment arm plus a CHW did not differ in results when compared with the assertive community treatment group alone, although for many outcomes both of these arms were superior to the brokered case management arm.120,121 The assertive community treatment arms (both with and without a CHW) had more contact with their case managers and were more satisfied than those in the brokered case management arm.120,121 Clients in the assertive community treatment also had fewer psychiatric symptoms at 18 months than clients in the brokered condition.120,121 Days in stable housing did not differ among groups.120,121

Knowledge. This RCT did not report outcomes for improved knowledge.

Behavior. This RCT did not report outcomes for improved behaviors.

Satisfaction. Clients in the assertive community treatment arms (both with and without a CHW) were more satisfied with their treatment program than clients in the brokered case management arm (satisfaction score ± standard deviation: 3.12 ± 0.57 versus 3.27 ± 0.42 versus 2.74 ± 0.68, P < 0.05).120,121

Health outcomes. Clients in the assertive community treatment arm plus a CHW did not differ in health outcome results as compared with the assertive community treatment group alone. Clients in the assertive community treatment arms (both with and without a CHW ) had fewer psychiatric symptoms as rated by the Brief Psychiatric Rating Scale (BPRS) at 18 months compared to baseline than did those in the brokered case management arm (baseline (SD)/18-month followup (SD): 57.97 (20.29)/38.77 (12.23) versus 53.54 (15.54)/39.96 (12.25) versus 50.60 (14.31)/51.60 (16.70), P = 0.001 for any difference among the three groups; P for comparison of either assertive community treatment arm not reported).120,121 Days in stable housing between groups did not differ across the groups.

Health care utilization. Use of health services did not differ between the assertive community treatment plus a CHW arm and the assertive community treatment group alone. Clients in the assertive community treatment arms (both with and without a CHW) had more days in contact with the program than did clients in the brokered case management arm (6.95 (4.91) versus 8.29 (7.51) versus 0.3 (0.49), P < 0.05).

Chronic disease management: asthma. Study characteristics. Two RCTs (three articles), one good-quality,96,97 and one fair-quality,100 examined outcomes of CHW interventions for asthma care among pediatric patients with persistent asthma. Both studies used a highly resource-intensive CHW model. Both studies provided comprehensive multifaceted interventions that included an environmental assessment, asthma action plan, education, referrals, allergy control mattress covers and pillows, vacuums, and cleaning supplies, pest management, and smoking cessation assistance to the high-intensity intervention arm, delivered over a year in several home visits. The Seattle King County Healthy Homes (SKCHH) project (Washington State) compared outcomes for children receiving a high-intensity multivisit home intervention with those for children receiving a low-intensity single home visit that included an environmental assessment, some education, and bedding encasements, followed by the full intervention after a year.96,97 The Community Action Against Asthma (CAAA) project adapted the SKCHH project to Detroit, Michigan, comparing a group receiving the high-intensity multivisit home intervention with a control group receiving an asthma information booklet and the full intervention after a year.100 Variations in measures of health behavior, outcomes, and health care utilization preclude quantitative synthesis of the results.

Overview of results. Two trials demonstrated that high-intensity CHW interventions are more effective than either low-intensity interventions or a control group in reducing unscheduled use of health care services and improving psychological outcomes for caregivers. Both studies demonstrated changes in behavior, such as increased use of bed encasements and vacuuming, associated with the materials distributed by the CHW, but not for other behaviors that may have required external or additional resources or change, such as removal of mold or reduced exposure to environmental tobacco smoke. Both studies demonstrated significant improvements within but not across trial arms for some measures of symptoms,96,97,100 reduced days with activity limitations, and reduced use of beta-agonists.96,97 Authors postulated that these results could be explained either because a minimal intervention may be effective for some outcomes or because of regression to the mean, temporal trends, or the Hawthorne effect (improvement in performance attributable to being observed) among the less intensive or control group participants.96,97 Nevertheless, for health outcomes demonstrating a difference between trial arms such as symptom days, the more intense arm was more effective than the less intense or control arm.

Knowledge. Neither study reported outcomes for improved knowledge of asthma triggers.

Behavior. Both studies examined a variety of behavioral changes (Table 30). Both studies reported increased use of materials provided—that is, mattress covers, pillows, and vacuums, suggesting reduced exposure to dust mites— in the more intense arm. Both studies failed to find differences between the two arms for behavioral changes associated with smoking cessation. Other behaviors that did not differ between arms included removal of pets and use of exhaust fans in the bathroom96,97 and removal of mold.100

Table 30 CHW asthma interventions and behavior

Author, Year Population Setting Sample Size Quality | Intensity of CHW Intervention | Study Groups | Results
Krieger et al., 2005;^96^ Krieger et al., 2002^97^ RCT Children ages 4–12 years with persistent asthma Low-income households in King County, Washington N: 274 Good | High | G1: Environmental assessment; asthma action plan; education and social support; mattress covers, pillows, vacuum, cleaning supplies; smoking cessation referral; 4–8 visits over 12 months G2: Environmental home assessment action plan, limited education, bedding encasements; full intervention after 12 months | Behavior, summary score of trigger reduction behaviors Across groups comparison: GEE coefficient (95% CI, 0.41 (−0.13–0.95); P = 0.141) Frequencies of actions to reduce dust exposure and the use of bedding encasements increased more in the high-intensity group; kitchen ventilation improved more in the low- intensity group. Neither group increased the frequency of washing sheets or dusting, nor reduced exposure to pets (although pet ownership was uncommon among participants) and smoking in the home; behavior summary score improved in both groups, and the across- group difference was not significant
Parker et al., 2008^100^ RCT Children ages 7–11 years with persistent asthma Southwest and eastside Detroit, Michigan N: 298 Fair | High | G1: Environmental assessment; asthma action plan based on allergy tests; education and social support; mattress covers, pillows, vacuum, cleaning supplies; counseling on environmental tobacco smoke; integrated pest management services; minimum 9 planned home visits over 12 months G2: Asthma information booklet, full intervention after 12 months | Intervention effect (or-intervention/or-control) Vacuum cleaner used: 29.5 (6.90, 126); P < 0.0001 Allergen cover on child's pillow: 19.7 (4.12, 94.2); P = 0.0006 Allergen cover on child's mattress: 9.70 (4.33, 21.7); P < 0.0001 Visible mold growth removed: 0.74 (0.33, 1.66); P = 0.47 Child is around people who smoke: 0.60 (0.28, 1.32); P = 0.20 Statistically significant intervention effect in the reduction of concentration of dog allergen per gram of bedroom dust (P < 0.001) but not for cockroach, dust mite, or cat allergen concentration

CI, confidence interval; GEE, generalized estimating equation; RCT, randomized controlled trial.

Satisfaction. Neither study reported outcomes for satisfaction.

Health outcomes. The SKCHH project reported on the number of symptom days in the past 2 weeks. The CAAA project looked at the occurrence of more than 2 symptom days per week for children not on any controller medication or corticosteroids (Table 31).

Table 31 CHW asthma interventions and health outcomes

Author, Year Study Design Population Setting Sample Size Quality | Intensity of CHW Intervention | Study Groups | Results
Krieger et al., 2005;^96^ Krieger et al., 2002^97^ RCT Children ages 4–12 years with persistent asthma Low-income households in King County, Washington N: 274 Good | High | G1: Environmental assessment; asthma action plan; education and social support; mattress covers, pillows, vacuum, cleaning supplies; smoking cessation referral; 4–8 visits over 12 months G2: Environmental home assessment action plan; limited education; bedding encasements; full intervention after 12 months | Pediatric Asthma Caregiver QoL Scale (score range 1–7 with higher scores indicating better QoL) Score at exit (G1 vs. G2): 5.6 vs. 5.4 GEE coefficient 0.58 (95% CI, 0.18–0.99), P = 0.005; NNT = 4.8 ITT analysis yielded similar results: improvements in QoL were greater in G1 (data NR, P = 0.009) Asthma symptom days (self-reported number of 24-hour periods during 2 weeks before interview with asthma symptoms: wheezing, tightness in chest, cough, shortness of breath, slowing down activities due to asthma, nighttime awakenings): G1 vs. G2 at exit: 3.2 vs. 3.9 GEE coefficient −1.24 (95% CI, −2.9 to 0.4), P = 0.138 Days with activity limitation over 2-week period Score at exit (G1 vs. G2): 1.5 vs. 1.7 GEE coefficient −1.5 (95% CI, −2.84 to −0.15), OR, 0.22 (0.06, 0.86), P = 0.29 Missed school in past 2 weeks: G1 vs. G2 at exit: 12.2% vs. 20.3% GEE coefficient −0.77 (95% CI, −1.70 to 0.16), OR, 0.46 (0.18, 1.18), P = 0.105 Days used controller medication over 2–week period: G1 vs. G2 at exit: 3.5 vs. 3.6 GEE coefficient −1.03 (95% CI, −2.79 to 0.73), P = 0.250 Days used beta2-agonist over 2-week period: G1 vs. G2 at exit: 4.0 vs. 4.0 GEE coefficient −0.23 (95% CI, −1.88 to 1.42), P = 0.781 Caregiver missed work in past 2 weeks: G1 vs. G2 at exit: 11.2% vs. 13.0% GEE coefficient 0.07 (95% CI, −0.91 to 1.0.5), OR, 1.07 (0.40, 2.85), P = 0.890
Parker et al., 2008^100^ RCT Children ages 7–11 years with persistent asthma Southwest and eastside Detroit, Michigan N: 298 Fair | High | G1: Environmental assessment; asthma action plan based on allergy tests; education and social support; mattress covers, pillows, vacuum, cleaning supplies; counseling on environmental tobacco smoke; integrated pest management services; minimum 9 planned home visits over 12 months G2: Asthma information booklet, full intervention after 12 months | Caregiver depressive symptoms measured by Center for Epidemiologic Studies Depression Scale (CES-D) mean at baseline/endpoint: G1: 1.62/1.54 G2: 1.58/1.64 P = 0.0218 Improvements in both instrumental and emotional social support combined and instrumental support alone were not statistically significant (data NR) Child's self-reported average asthma symptom frequency: G1: symptoms occurred less frequently at baseline for all 8 symptoms assessed G2: symptoms occurred less frequently for 6 of 8 symptoms Persistent cough at baseline, postintervention (on a 6-point scale, higher is worse): G1: 3.81, 3.36 G2: 3.48, 3.44 P = 0.034 Cough with exercise at baseline, postintervention (on a 6-point scale, higher is worse): G1: 4.27, 3.69 G2: 3.80, 3.66 P = 0.017 Has any symptom more than 2 days per week and not on a corticosteroid G1 (pre/post) vs. G2 (pre/post) intervention effect (95% CI): 60/42 vs. 51/46; 0.56 (0.29 to 1.06); P = 0.073 Has any symptom more than 2 days per week and not on any controller G1 (pre/post) vs. G2 (pre/post) intervention effect (95% CI): 53/32 vs. 38/37; 0.39 (0.20 to 0.73); P = 0.004

CI, confidence interval; GEE, generalized estimating equation; ITT, intention to treat; NNT, number needed to treated; NR, not reported; OR, odds ratio; QoL, quality of life; vs., versus.

Results from these two trials were mixed. The Seattle (SKCHH) project reported nonsignificant differences between the arms in the reduction in symptoms days, whereas the Detroit (CAAA) project found significant differences between the trial arms for children not on any controller medication (OR, 0.39 [95 percent CI, 0.20–0.73]).96,97 The differences between trial arms in reduction of symptom days was not statistically significant in the subset of children not on corticosteroids.100

The Seattle (SKCHH) project also examined differences in trial arms in days with activity limitation, use of beta-agonists, use of controller medications, missed school days for the child, and missed caregiver workdays. With the exception of days with activity limitations, the study found no differences between the intervention arms.96,97 It also found a significantly higher increase in caregiver quality of life (measured by the Center for Epidemiologic Studies Depression Scale in the more intense arm (coefficient for difference between groups in mean change from exit to baseline: 0.58 [95 percent CI, 0.18–0.99]).96,97

The Detroit (CAAA) project found significant improvements in symptoms for both intervention and control arms, but differences were statistically significant only for coughing with exercise and persistent cough. It also found significant differences between trial arms in some but not all measures of lung function; these results could potentially be explained by seasonal influences, changes in instrumentation, and inadequate power.100 Finally, it reported a statistically significant reduction (P = 0.0218) in caregiver depressive symptoms (measured by the Center for Epidemiologic Studies Depression Scale) in the intervention arm (mean value at baseline and followup: 1.62 and 1.54) compared to a rise in depressive symptoms in the control arm (mean value at baseline and followup: 1.58 to 1.64). The study found no statistically significant differences between the two groups in changes in social support between baseline and the endpoint.100

Health care utilization. Both studies (Table 32). found a significant difference in the reduction in unscheduled medical care—emergency room visits, hospitalizations, and unscheduled doctor visits—favoring the more intense intervention at three points: 2 months (OR: 0.38; 95% CI, 0.16–0.89),96,97 3onths (OR: 0.43; 95% CI, 0.23–0.80),100 and 12 months (OR: 0.40; 95% CI, 0.22–0.74).100

Table 32 CHW asthma interventions and health care utilization

Author, Year Population Setting Sample Size Quality | Intensity of CHW Intervention | Study Groups | Results
Krieger et al., 2005;^96^ Krieger et al., 2002^97^ Children ages 4–12 years with persistent asthma Low-income households in King County, Washington N: 274 Good | High | G1: Environmental assessment; asthma action plan; education and social support; mattress covers, pillows, vacuum, cleaning supplies; smoking cessation referral; 4 to 8 visits over 12 months G2: Environmental home assessment action plan, limited education, bedding encasements; full intervention after 12 months | Urgent health services used over 2 months G1 vs. G2 at exit: 8.4% vs. 16.4% GEE coefficient −0.97 (95% CI, −1.8 to −0.12), OR 0.38 (0.16, 0.89), P = 0.026; NNT = 12.9 ITT analysis yielded similar results: improvements in urgent health services were greater in G1 (data NR, P = 0.062)
Parker et al., 2008 100 Children ages 7–11 years with persistent asthma Southwest and eastside Detroit, Michigan N: 298 Fair | High | G1: Environmental assessment; asthma action plan based on allergy tests; education and social support; mattress covers, pillows, vacuum, cleaning supplies; counseling on environmental tobacco smoke; integrated pest management services; minimum 9 planned home visits over 12 months G2: Asthma information booklet, full intervention after 12 months | Reduction in unscheduled health care utilization for asthma Percentage needed unscheduled medical care–G1 (pre/post) vs. G2 (pre/post); intervention effect (95% CI): In past 3 months: 50/45 vs. 42/56; 0.43 (0.23 to 0.80); P = 0.007 In past 12 months: 65/59 vs. 58/73; 0.40 (0.22 to 0.74); P = 0.004

CI; confidence interval; GEE, generalized estimating equation; ITT, intention to treat; NNT, number not treated; NR, not reported; OR, odds ratio; RCT, randomized controlled trial.

## KQ 3: Cost-Effectiveness of Community Health Worker Interventions

### Overview of Economic Analyses

A total of nine studies that met inclusion criteria for this review contained information about intervention costs, cost-effectiveness, or cost-benefits. We focused here on the six studies that also demonstrated effectiveness of the CHW intervention, either as compared with the alternatives that were analyzed or as compared with baseline, or usual, care.17-22,75,80,96,104,121 The studies on CHWs that included economic information varied a great deal in terms of the populations targeted for intervention, the types of interventions implemented and the settings for those interventions, the alternatives that were analyzed, and the outcomes the interventions sought to impact.

Targeted populations, for example, ranged from Latina women to low-income infants and children. The types of interventions using CHWs as a study arm included early childhood and child health interventions, cancer screening interventions, and chronic disease management interventions. Some studies evaluated alternatives that varied intensity levels for the CHW intervention; others compared the CHW intervention without nurse-delivered interventions; and others compared the CHW intervention with lower intensity alternatives that did not involve direct interaction with targeted patients (e.g., providing written materials only). Study outcomes also varied a great deal across studies, reflecting the diversity of types of interventions and targeted populations (e.g., outcomes related to use of health care, child health and development, and impacts on usual activities such as work or school). Intervention settings also varied; some CHW interventions focused on working with participants in their homes, one focused on working with homeless individuals, and another took place in urban churches.

The three studies with economic information that we eventually excluded involved (1) a diet change intervention that targeted Hispanic women,64 (2) an environmental tobacco smoke intervention that targeted young Latino children,67 and (3) a children’s immunization intervention that compared CHW interventions with mail or telephone interventions for raising children’s immunization rates.69,70 These three studies produced no statistically significant impact on CHW intervention groups as compared with outcomes in the control groups.

In the discussion below, we cite only the articles with data specific to the cost-analysis; studies spanned several other citations specific to outcomes not relevant to the discussion below.

Economics: cancer screening. Study characteristics. Two studies (one trial and one prospective cohort) evaluated program costs or cost-effectiveness for CHW interventions that sought to improve women’s mammography rates.17,22 The ROSE study targeted low-income, rural white, African-American, and Native-American women in North Carolina ages 40 years and older, all of whom had not had a mammogram in the previous 12 months.17,18 These women were randomly assigned to a high-intensity CHW intervention, which involved three home visits with followup telephone calls and mailings, or to a comparison group. The CHW intervention was delivered for a period of 12 to 14 months. The LAMP CHW study collected data on program costs and cost-effectiveness for a low-intensity cancer screening CHW intervention.19–22,104 The intervention was a church-based telephone counseling program that targeted female church members ages 50 to 80 years to promote mammography. Some of these women had obtained mammograms 1 to 2 years before the initial survey and within the 2-year window before that (“adherent” group), whereas others had not (“nonadherent” group). Church volunteers made one telephone call per 12-month period to encourage and address barriers to mammography.

Overview of economic analysis results. Both studies report program costs and the costs per additional mammography screening.17,22 Both studies estimated program costs using a program or funder perspective (i.e., including only those costs that would be incurred by a prevention program to deliver the intervention); that is, they did not employ a societal perspective. Because the LAMP study used volunteer labor, the costs of the intervention from the program perspective are necessarily low compared with the costs of the ROSE intervention, which paid their CHWs. To better understand what costs would be if CHWs had to be hired to deliver the LAMP intervention, Stockdale et al.22 also report two alternative program cost estimates—one that values volunteer time at the minimum wage and another that values volunteer time at the average wage rate.

Measures of effectiveness for economic analysis. The main effectiveness outcome that both studies used for their economic analyses was mammogram receipt in the 12 months before a followup survey. The ROSE study outcomes were based on review of a woman’s medical record.17,22 The LAMP study outcomes were based on participants’ self-reports via a telephone interview; it also estimated life-years saved based on a model of screening, diagnosis, and treatment for breast cancer.22

Economic outcomes. The total cost of the ROSE intervention was estimated to be $329,054,^17^ which translates to approximately $404 per participant, based on the 815 participants who fully participated in the intervention and data collection. The year of costs was not reported for the ROSE study. Program costs for the LAMP intervention were estimated to be $11 per participant in 1997 dollars when the opportunity cost of CHW volunteers’ time was excluded from the cost calculation. Costs were estimated at $28 per person when CHW volunteers’ time was valued at the minimum wage and $52 per person when an average wage rate for each type of volunteer was used (1997 dollars).22 To compare ROSE and LAMP costs, we assumed that the ROSE costs are in 2000 dollars (the midpoint of the study time period, 1998 through 2002). Using the consumer price index for all urban consumers (CPI-U) to adjust the LAMP intervention cost of $52 per participant in 1997 dollars to 2000 dollars yields an estimate of $56 per LAMP participant, as contrasted with the high-intensity ROSE intervention cost of about $404 per participant.

Both studies also reported costs per additional screening.17,22 Paskett et al. estimated the impact of the ROSE intervention to be 66 additional mammograms in the CHW intervention group, resulting in a cost-effectiveness ratio of $4,986 per additional mammogram (assumed 2000 dollars).17 Stockdale et al. estimated the impact of the LAMP intervention to be 3.24 additional mammography screenings for each of the 45 churches that participated in the study, resulting in an estimated cost per additional screening of $903 (1997 dollars) when CHW volunteers’ time was valued at the average wage rate.22 Although these findings appear to suggest that the LAMP intervention had a much lower cost per additional mammogram received than did the ROSE intervention, the effectiveness and cost-effectiveness results are not comparable between these two studies because the LAMP intervention targeted women who were both adherent and nonadherent with screening guidelines, whereas the ROSE intervention targeted only nonadherent women. Focusing on results for the nonadherent LAMP participants only, the estimated intervention effectiveness is 1.46 additional screenings per church per year (not statistically significant), which we estimate to produce a cost-effectiveness ratio of $2,005 per additional mammography screening in 1997 dollars, or $2,151 in 2000 dollars, when the time of CHWs is valued using expected wage rates.

Stockdale et al. also estimated the cost per life-year saved by the LAMP intervention and subsequent mammography screening as $46,308 (1997 dollars),22 when CHW time was valued using expected wage rates ($33,632 plus the estimated cost per life-year saved for mammography screening of $12,676).

Economics: chronic disease management. Study characteristics. Two studies provided economic information on the management of chronic diseases; both studies are described in more detail in the last section of KQ 2. One study evaluated an asthma control intervention for children;96 the other evaluated an intervention to prevent homelessness in patients with mental illness.121

The asthma intervention, known as the Seattle King County Healthy Homes (SKCHH) project, evaluated a 1-year high-intensity CHW intervention approach, involving five to nine CHW home visits.96 The investigators compared this high-intensity intervention with a low-intensity version that involved only one CHW home visit and evaluated health care utilization and costs for participants, intervention program costs, and other measures related to asthma control, quality of life, and productivity.

The homelessness prevention intervention compared three alternative case management approaches for people with mental illness at high risk of homelessness:

- brokered case management—a low-intensity intervention that can be viewed as the baseline, or usual care, approach;
- assertive community treatment—a high-intensity intervention that involves frequent interaction with the client and assistance with a host of activities and social service acquisition; and
- assertive community treatment with CHWs—a high-intensity CHW intervention that consists of assertive community treatment, adding a CHW to interact with and assist clients.121

Each intervention was provided over 18 months. Key outcomes were health care and social services utilization, program costs, and pre- and postintervention measures of 6 months of costs for health care and social services among study participants.

Overview of economic analysis results. Both studies report program costs per participant from the program perspective. For the Seattle study, Krieger et al.96 estimated the cost of the 12-month intervention by summing payments for salary and fringe benefits, supplies, rent, travel, and office expenses and adding indirect costs of 13 percent. For the homelessness prevention study, Wolff et al.121 estimated the additional intervention program costs of assertive community treatment, with and without CHWs, as the costs above those for brokered case management; their estimates values CHW time at the minimum wage.

Both studies estimated the impact of the intervention on health care and/or social services costs for program participants. For example, Krieger et al. assessed the pre- and postintervention costs of urgent care services for both CHW intervention arms (high and low intensity).96 Wolff et al. also assessed the pre- and postintervention costs of the following services for program participants in all three intervention arms: mental and physical health, vocational and educational, residential, and supportive social.121

Measures of effectiveness for economic analysis. Neither study created a measure of the costs per unit of program effectiveness (e.g., cost per additional day in stable housing or cost per additional day of school attendance). Instead, both studies estimated program cost savings or potential cost savings by comparing health care or social services costs in the preintervention time period with costs in the postintervention time period.

For example, the Seattle study estimated urgent care costs for the targeted children in the 2 months before the start of the intervention and compared these values without analogous costs in the 2-month period before the exit interview.96 For this work, Krieger et al. defined urgent care costs as the costs of hospital admissions, emergency department visits, and unscheduled clinic visits.96 Because this intervention sought to reduce use of urgent health care services among participants with asthma, a reduction in urgent care costs for participants may be viewed as cost savings attributable to the intervention.

The homelessness prevention intervention also compared preintervention and postintervention costs for participants in each of the study arms. For this work, Wolff et al. calculated costs for the following services, by study arm:

- mental health inpatient,
- mental health outpatient,
- physical health inpatient,
- physical health outpatient,
- vocational and educational,
- residential,
- cash social support, and
- in-kind social support.121

Wolff et al. also provided a total cost amount that summed the per-patient costs for all of the above services and included the intervention cost for assertive community treatment (with or without CHWs).121 However, reductions in these total or specific services costs should not be viewed as cost savings attributable to the intervention because utilization and costs of some services might be expected to rise, rather than fall, as the result of a successful intervention. For example, successful assertive community treatment interventions might lead to larger pre/postintervention increases in vocational and educational service costs than a brokered case management approach.

Economic outcomes. In the Seattle program, costs for the high-intensity CHW intervention were $1,124 per child higher in 2001 dollars than costs for the low-intensity CHW intervention.96 Estimated costs for the low-intensity asthma intervention were not provided.96

For the homelessness prevention intervention, annual program costs were $6,200 per participant for the assertive community treatment intervention with CHWs and $6,440 per participant for assertive community treatment only.121 These cost estimates are in 1992 dollars and are in addition to costs for brokered case management—costs that were not reported in the article. Adjusting these cost estimates to 2001 dollars using the CPI-U, we estimate the costs of assertive community treatment with CHWs to be $7,826 per patient and the costs of assertive community treatment only to be $8,129 per patient, in addition to costs for brokered case management.

For the Seattle study of children with asthma, Krieger et al. also provided estimates of pre/postintervention health care cost reductions attributable to the CHW asthma intervention.96 Comparing urgent care costs in the 2 months before the intervention with costs in the 2 months at the end of the intervention, they estimated cost reductions of $201 to $334 per child in 2001 dollars.96 For the low-intensity CHW group, analogous cost reductions were $185 to $315 per child. Assuming these cost reductions persist for 1 year, estimated annual cost reductions are $1,200 to $2,000 per child for the high-intensity CHW intervention in 2001 dollars. Krieger et al. also discussed the cost-effectiveness of the high-intensity intervention relative to the low-intensity approach.96 They found savings in urgent care costs for the high intervention group relative to the low intervention group of $57 to $80 per child over a 2-month period.96 The authors reported that if these cost reductions were to last for 3 to 4 years, the high-intensity intervention would be cost saving relative to the low-intensity intervention. Whether assuming the same level of reduced urgent care utilization and costs for several years postintervention is reasonable, however, remains unclear. The authors did find that urgent care utilization remained low in the high-intensity group for at least 6 months following the intervention.96

For the study of homeless mentally ill participants, Wolff et al. conducted regression analyses to explore whether study arms differed in their measures of total costs over the 18-month study period.121 They found no difference in total costs across study arms after controlling for patients’ costs in the preintervention period.121 They also compared 6-month costs in the preintervention period to 6-month costs for three separate postintervention periods (1 to 6 months, 7 to 12 months, and 13 to 18 months). At least in part because the number of participants in each intervention arm was relatively small (N = 35, 28, and 22, respectively), postintervention costs varied a great deal across time periods. The authors point out that, when comparing the preintervention period with the first 6 months’ postintervention period, inpatient mental health services costs fell $1,315 for assertive community treatment with CHWs, rose almost $4,500 for assertive community treatment only, and rose more than $8,000 for brokered case management.121 Considering the second 6-month period of the intervention, inpatient mental health services costs fell by more ($4,400 per participant) in the assertive community treatment only group than in the assertive community treatment with CHWs group ($2,651 per participant). Inpatient mental health services costs also declined in that time period for the brokered case management group ($1,252 per participant). All of these cost estimates are in 1992 dollars.

The cost estimates for health and social services that Wolff et al.121 report are difficult to interpret using the currently recommended framework for performing and evaluating cost-effectiveness analyses.130,131 The recommended approach for performing cost-effectiveness analysis is to specify the perspective of the study a priori and to calculate net costs for use in cost-effectiveness evaluation as intervention costs less any costs for health care or other relevant variables (including productivity losses) averted by the intervention. The societal perspective is recommended for economic evaluation, which implies that all costs should be included, regardless of who bears them. Although the Wolff et al.121 article implies that the intent was to estimate costs from the societal perspective, their measure of total costs excludes criminal justice and family burden costs (mentioned as a limitation), it excludes productivity costs, and it includes societal transfers (cash and in-kind support) that are not recommended for inclusion in economic analyses from the societal perspective. The presentation of costs in three different intervention time periods also makes it difficult to interpret the Wolff et al. estimates, because costs differed a great deal over time for each intervention arm.121 Finally, the total cost measures they presented cannot readily be used in economic evaluations without some adjustments. Their total cost estimates represent the sum of intervention costs and specific health care and social services costs. These total cost estimates vary a great deal across intervention arms (including for the preintervention period) and across time within each intervention arm. In contrast, the recommended estimates for use in economic evaluations are measures of net costs that provide a single measure of costs for each intervention arm that subtract from intervention costs the health care, productivity, and other related cost reductions attributable to the intervention.131

Economics: child health. Study characteristics. Two studies evaluated program costs for CHW interventions that sought to improve child health.75,80 One study, set in Maryland, evaluated the impact of a high-intensity CHW intervention for children with nonorganic failure to thrive in a low-income urban setting. As reported by Black et al., children diagnosed with failure to thrive were randomized to receive either the CHW intervention, which involved the delivery of clinical services plus weekly home visits from a trained CHW, or the clinical intervention only.75 The Home Visitation 2000 RCT targeted low-income, pregnant women for a home visiting intervention that involved prenatal home visits, followed by home visits every 1 to 2 months until the target child was 2 years of age.80 In this study, Olds et al. compared the impact of using CHWs to deliver the home visiting intervention with the impact of using nurses.80 In addition to program costs, it evaluated several child health and developmental outcomes (e.g., mother-child interaction, quality of the home environment, child developmental outcomes).

Overview of economic analysis results. Both studies reported intervention program costs. Cost components for the failure-to-thrive trial included salaries for the CHW or nurse, materials costs, transportation costs, costs of police service, and a 10 percent overhead fee.75 Olds et al. provided a per-family total cost of the 2.5 year Home Visitation 2000 trial,80 but they did not specify details on what was included in the cost estimate.

Measures of effectiveness for economic analysis. Because both of these studies reported only the intervention costs, they did not examine intervention costs in relationship to outcomes. Thus we had no measures of intervention effectiveness for these economic analyses.

Economic outcomes. Annual program costs for the failure-to-thrive CHW intervention were $2,828 per child in 1993 dollars.75 Although the article did not explicitly state this, we assumed that this cost estimate reflects the additional costs of the CHW intervention relative to the clinical intervention (usual care). When adjusted to 2002 dollars using the CPI-U, the CHW intervention for these children has an estimated annual cost of $3,520 per child. For the Home Visitation 2000 RCT, program costs were $9,140 per family in 2002 dollars for the nurse home visitation arm and $6,162 per family for the CHW intervention arm.80 These costs are for the full 2.5 years of the program. Dividing these estimates by 2.5, we estimate annual costs of $3,656 per family for the nurse home visitation intervention and $2,465 for the CHW home visitation intervention—both in 2002 dollars.

Economics: summary of findings. Table 33 summarizes findings from the six CHW intervention articles that provided information on program costs and other economic outcomes (presented in the order of discussion above, by clinical context). Cost estimates are shown as presented in each article, but we also report each cost estimate adjusted to 2008 dollars using the CPI-U. Although adjusting some of the cost estimates using the medical care component of the CPI might have been more appropriate, because that component accounts for faster growth in prices in the health care sector than in other parts of the US economy, we used the CPI-U because all studies relied on nonmedical labor to provide the CHW intervention.

Table 33 Summary of economic analyses of CHW interventions

Author, Year | Intervention Description | Annual Intervention Program Costs Per Participant, Year of Dollars Specified or Assumed | Annual Intervention Program Costs, 2008 Dollars | Results of Other Economic Analyses
Stockdale et al., 2000^22^ | Mammography screening intervention | $52 (1997) | $70 | $903 per additional mammography screening, 1997$ $46,308 per life-year saved for intervention plus mammogram, 1997$
Paskett et al., 2006^17^ | Mammography screening intervention | $404 (2000 assumed) | $505 | $4,986 per additional mammography screening, (2000$ assumed)
Krieger et al., 2005^96^ | Asthma management intervention | $1,124 (2001) | $1,366 | $201–$334 reduced urgent care costs per child, high- intensity CHW intervention, 2001$
Wolff et al., 1997^121^ | Homelessness prevention intervention | $6,200 (1992) (CHW intervention) | $9,514 | Reductions in inpatient mental health services costs for CHW intervention relative to usual care in all intervention time periods
Olds et al., 2002^80^ | Child health and development intervention | $2,565 (2002) (CHW intervention) | $3,070 | None
Black et al., 1995^75^ | Child health intervention | $2,828 (1993) | $4,214 | None

CHW, community health worker.

## KQ 4: Training of Community Health Workers

### Characteristics of Training for Community Health Workers

Overview. Study characteristics. As noted in Chapter 2, an inclusion criterion specific to KQ 4 was that all studies reported on changes in knowledge or skills among CHWs after training. Although we identified 46 citations that were potential includes,111,132–176 only 9 studies (10 citations) provided evidence of changes in knowledge or skills among CHWs after training.137,141,143,147–150,155,169,176

All included studies were set in minority or underserved communities. Three focused on cancer prevention,137,141,143,176 two on cardiovascular disease,147,149 and one each on health promotion,169 tobacco cessation,150 salmonella prevention in the manufacture of queso fresco,155 and on health insurance enrollment, immunizations, and asthma prevention.148

The studies included in this section spanned a variety of models of CHW interventions. Five studies relied on volunteers;137,141,149,155,169,176 other studies either paid CHWs or did not report on payment status. The size of the intervention effort also varied: the number of CHWs trained through these programs ranged from 4^147^ to 1,504.^148^ The educational background and prior training of the CHWs undergoing training were rarely reported: one study reported that 98 percent (of 79 CHWs) had either a college bachelor’s or graduate degree,137 whereas another study reported that all trainees (4 CHWs) had 10 years of prior experience as CHWs.147 Studies also varied in their degree of specificity in reporting eligibility criteria for CHWs. The contribution of CHWs to developing training materials varied, ranging from intensive involvement in pretesting to no involvement. Studies also varied in their reporting on training components; in the following sections, we describe reported data on components of training.

Training on cultural competence. Two studies reported training for cultural competence, but they provided no details on the content, method, and number of sessions.148,149

Training on recruitment and retention process skills. Two studies reported training on recruitment and retention.141,150,176 One study noted that client recruitment was addressed, but the content, method, and number of sessions was not reported.150 The other recorded five 2-hour sessions covering recruitment strategies and role-playing practice.141,176

Training on intake and assessment. One study reported training for intake and assessment, specifically on community mobilization, communication skills, and outreach strategies, but it provided no details on the content, method, and number of sessions.148 A second study noted two training sessions for assessment and role-play.147

Training on protocol delivery. Two studies reported on training on protocol delivery.147,148 One provided no further details,148 and the second listed health education counseling as part of the curriculum, and included role play for cancer screening counseling sessions and cardiovascular disease counseling sessions that was followed by external feedback from a clinical psychologist.147

Training on health topic. The purpose of training CHWs on health topics was to prepare them to educate participants. Seven studies described the health content of their training in some detail;137,141,143,147,150,155,169,176 all provided evidence of change in knowledge of skills after training (Table 34). Only two reported significance tests.

Table 34 CHW training and evaluation results

Author, Year Study Name Setting: Geography Setting: Organizational, Social, Cultural | Objective or Aim of Training | Training on Content/Health Topic | Evaluation and Testing Results of the Curriculum (Improvements in CHW Knowledge)
Balcazar et al., 2006^149^ Salud Para Su Corazon- National Council of La Raza Escondido, California; Chicago, Illinois; Ojo Caliente, New Mexico Latino communities | To promote heart-healthy behaviors among Latinos | Not described | The closed-format pre/posttest scores reported a score of 74% correct for the pretest and 100% for the posttest (n = 11). Differences in pre-post promotora knowledge score changes (N = 29) were statistically significant (P < 0.05) but data reported in bar graph only
Beck et al., 2007^143^ Center for Health Communities' cancer education program Milwaukee County, Wisconsin African- American churches | To train the trainer in cancer education | 2 90-minute train-the- trainer workshops | Pre/post percentage correct— Ability to define cancer: General: 89/93; breast: 79/86; colon: 15/57; prostate: 80/75 Ability to identify signs and symptoms of cancer: General: NA; breast: 71/88; colon: 81/93; prostate: 40/75 Ability to identify screening recommendations: General: NA; breast 67/67; colon: NA; prostate: 80/75 Ability to identify risk factors: General: 59/85; breast: 54/92; colon: 19/89; prostate: 40/75 Ability to identify strategies to reduce cancer risk: General: 70/78; breast: 8/33; colon: 92/96; prostate: 20/75
Bell et al.,1999^155^ Abuela Project Yakima County, Washington Hispanic communities | To train Hispanic women to make queso fresco that was authentic in taste and texture but did not use raw milk in an effort to reduce the incidence of Salmonella serotype Typhimurium infections resulting from eating queso fresco made from raw milk | Workshops on how to make new queso fresco recipe (i.e., without raw milk) | Pretraining/posttraining: Recognized health risks associated with eating unpasteurized milk and cheese (N): 10/14; 14/15 Make queso fresco with fresh unpasteurized milk: 6/12; 1/15.
Kuhajda et al., 2006^147^ Pine Apple Heart Disease and Stroke Project Pine Apple, Alabama African-American women in rural southern community | To train CHWs for heart disease and stroke and in skills for counseling and assessing high-risk women in the Pine Apple clinic | Topics addressed in training included cardiovascular disease; developing action plans (heart attack, congestive heart failure, stroke); high blood pressure; tobacco control; cancer (lung, colorectal, breast, cervical) | Counseling CHWs' responses on pre/post training questionnaires showed increases in knowledge and self-reported behaviors in each of the following areas: heart disease and stroke prevention strategies, cancer prevention strategies, heart attack or stroke signs and symptoms, cancer signs and symptoms, current heart disease and stroke prevention activities, current cancer prevention activities. Data reported in bar graph only
Martinez-Bristow et al., 2006^150^ Tobacco Free El Paso El Paso, Texas Neighborhood clinics | To train Spanish- speaking counselors to deliver tobacco cessation interventions | 5 days of training for each level of certification for nicotine addiction | Results from pre/posttest measuring self-confidence suggest that participants understood training material; data NR Mean satisfaction scores (1 = definitely not confident to 5 = definitely confident) high for recipients of each certification: Beginner: 4.8, intermediate: 4.7, advanced: 4.6
Navarro et al., 2007^141,176^ Por La Vida Cuidandome San Diego, California Latino communities | To train community health advisors to conduct interactive educational group sessions and train-the- trainer and their "learning partners" | Manual had sessions for understanding female body, breast cancer, Pap test, breast health, risks | Changes in knowledge and behavior, pre/post test for primary participants; and learning partners (percentage naming the following test for breast/cervical cancer early detection): BSE 58.6/74.7; 46.4/56.3 Clinical breast exam: 29.1/28.8; 28.8/20.7 Mammography: 49.8/71.2; 45.0/63.1 Pap test: 84.6/91.9; 79.3/85.1 Knows BSE: 90.5/99.3; 82.4/93.2 Knows mammography recommendations: 32.3/55.8; 27.4/38.1 Names ≥ 1 breast cancer symptom: 75.1/96.8; 70.3/94.1 Names ≥ 1 treatment for breast cancer: 40.0/65.6; 27.9/45.0 Names ≥ 1 risk factor: 8.1/16.5; 6.8/7.2 Names ≥ 1 factor for cervical cancer: 30.9/59.6; 24.3/35.1 BSE in past month: 62.3/87.4; 55.9/71.5 Mammography ever: 63.3/70.0; 66.7/68.3 Pap test ever: 92.3/97.9; 88.3/92.8
Perez et al., 2006^148^ Northern Manhattan Community Voices Collaborative Northern Manhattan, New York, neighborhoods | To train community health workers, focusing on facilitating insurance enrollment, child immunization, and asthma management | Yes, but not described | Pre/post scores in competency and knowledge (gains, percentage change): Insurance enrollment: 24%/72% (gain = 48%; percentage change = 200; n tested = 61) Immunization promotion: 83%/96% (gain = 48%; percentage change = 16; n tested = 472) Asthma management: 63%/83% (gain = 20%; percentage change = 32; n tested = 499)
Williams et al., 1996^169^ No study name Atlanta and Fort Valley, Georgia Older African Americans | To raise awareness of and increase participation of older African Americans in health promotion activities | Training divided into 3 categories: G1: chronic disease education and self-care G2: lifestyle education G3: consumer education Topics for these categories developed into 12 training modules | Obtained score ≥80 on pre/posttest for hypertension and diabetes training sessions: Urban, low to middle income: 32%/60% Inner-city, low income: 11%/72% Rural, mixed income: 28%/93%
Yu et al., 2007^137^ No study name Southeast Michigan Chinese communities | To increase the self- efficacy of CHWs in conducting breast cancer screening promotion | Training manual had 9 chapters and 5 appendices (1 was a bilingual glossary of medical terms); content includes socieodemographic characteristics and special health concerns, outreach strategies, effective communication skills for promoting screening. Also a web site, PowerPoint slides, and audio recordings available | Change in trainees' knowledge and self-efficacy Knowledge—mean number of correct answers pre (SD)/post (SD): 6 (1.4)/8 (1.1), P < 0.001 Self-efficacy—mean score pre (SD)/post (SD): 61.0 (11.5)/65.0 (9.2), P = 0.016

BSE, breast self examination; CHW, community health workers; CVD, cardiovascular disease; NA, not applicable; SD, standard deviation.

Training on evaluation. A single study reported evaluation as one of the seven core modules in their curriculum but provided no further details.148

Other training. Four studies reported training on communication skills,137,148,149,176 and a single study reported on making referrals.176 Training curricula may well have included additional elements that were not reported.

### Patient Outcomes of Community Health Worker Training

We did not identify any studies that reported on patient health outcomes of CHW interventions that were linked to characteristics of training.