# Methods

In this chapter, we document the procedures that the RTI International–University of North Carolina Evidence-based Practice Center (RTI–UNC EPC) used to develop this comprehensive evidence report on community health workers (CHWs). The team was led by a senior health services researcher (Meera Viswanathan, Ph.D., Study Director), and included a physician trained in internal medicine and pediatrics (Dan Jonas, M.D., M.P.H.), a general internist (Jennifer Kraschnewski, M.D.), a preventive medicine physician (Brett Nishikawa, M.D.), an economist (Amanda Honeycutt, Ph.D.), and two EPC staff members, Laura Morgan, M.A., and Patricia Thieda, M.A.

We describe our inclusion and exclusion criteria, search and retrieval process, and methods of abstracting relevant information from the eligible articles to generate evidence tables. We also discuss our criteria for grading the quality of individual articles and for rating the strength of the evidence as a whole.

## Literature Review Methods

### Inclusion and Exclusion Criteria

Our inclusion and exclusion criteria are documented in Table 1. As noted in Chapter 1, this systematic review focuses on characteristics, outcomes, cost-effectiveness, and training of CHWs. We restricted our searches to the United States so that we could have data relevant to domestic health care concerns. We also restricted our searches to studies published in 1980 or thereafter to ensure that results had relevance to current practice.

Table 1 Inclusion/exclusion criteria

Category | Criteria
Populations | All study populations with a CHW intervention
Interventions | Intervention must be delivered by CHWs, not peer counselors or health care professionals. A CHW:; - Performs health-related tasks to create a bridge between community members, especially hard-to-reach populations, and the health care system (i.e., performs tasks extending beyond peer counseling or peer support alone).; - Has health training associated with the intervention; training is shorter than that of a professional worker (i.e., training does not form part of a tertiary education certificate).; - Is recognized (or can be identified) as a member of the community in which he or she works, defined by but not limited to, geographic location, race or ethnicity, and exposure or disease status.
Comparisons | KQs 1, 2, 3: CHW intervention must have a comparison arm; all comparisons admissible as long as the effect of the CHW intervention can be abstracted KQ 4: No comparisons required
Outcomes | KQ 1: Interaction with clients KQ 2: Knowledge, satisfaction, behavior, health outcomes, and health care utilization KQ 3: Cost data KQ 4: Training characteristics
Time period | 1980 to November 14, 2008
Study settings and geography | United States
Publication languages | English only
Admissible evidence (study design and other criteria) | [underlined: Admissible designs] controlled trials (n ≥ 40), nonrandomized controlled trials (n ≥ 40), systematic reviews, meta-analyses, prospective trials with historical controls (n ≥ 40) [underlined: Other criteria]; - Original research studies must provide sufficient detail regarding methods and results to enable use and adjustment of the data and results; - Relevant outcomes must be able to be abstracted from data presented in the papers; - Effect of CHW intervention must be abstractable; - KQ 4: CHW interventions must provide pre-training and post- training evaluation of CHW knowledge or skills

We excluded studies that (1) were published in languages other than English (given the available time and resources); (2) did not report information pertinent to the key clinical questions; (3) had fewer than 40 subjects for randomized controlled trials (RCTs) or nonrandomized cohorts with comparisons; and (4) were not original studies.

A key criterion for inclusion was the requirement that the effect of the CHW had to be abstractable. As a result of this criterion, our review is limited to studies for which the effect of the CHW intervention can be isolated; we excluded 38 studies in which the outcome of the intervention could not be attributed to the CHW. These studies often compared usual care to a combination of interventions that may have included CHWs as one of several components and did not distinguish between the effect of the CHW and other components. Another key criterion was the requirement that the intervention included CHWs. As a result, we excluded studies that relied on peer counselors (13 studies).

For key questions (KQs) 1, 2, and 3, we required that the CHW intervention be compared with an alternative; we excluded 70 studies without comparison arms. For KQ 4, we required that the description of training for CHWs be supported by pre- and post-training evaluation data; we excluded 34 studies without such data.

### Literature Search and Retrieval Process

Databases. We searched three electronic databases—MEDLINE^®^, Cochrane Collaboration resources, and Cumulative Index to Nursing and Allied Health Literature (CINAHL). We also hand-searched the reference lists of relevant articles to make sure that we did not miss any relevant studies. We consulted with our Technical Expert Panel (TEP) about any studies or trials that were currently under way or that had not yet been published.

Search terms. Based on the inclusion/exclusion criteria above, we generated a list of Medical Subject Heading (MeSH) search terms (Table 2 and Appendix A). Our TEP also reviewed these terms to ensure that we were not missing any critical areas, and this list represents our collective decisions as to the MeSH terms used for all MEDLINE searches.

Table 2 MEDLINE search strategy and unduplicated results for April 2008

Search number | Search Term | Yield
#2 | Search “Community Health Aides”[MeSH] OR “health advisor” OR “health worker” OR “health advocate” OR “health paraprofessional” OR “community health representative” OR “outreach worker” OR dumas OR promotoras OR embajadores OR consejeras | 6,051
#3 | Search “Community Health Aides”[MeSH] OR “health advisor” OR “health worker” OR “health advocate” OR “health paraprofessional” OR “community health representative” OR “outreach worker” OR dumas OR promotoras OR embajadores OR consejeras Limits: Humans, English | 3,031
#6 | Search ((“Outcome Assessment (Health Care)”[MeSH] OR “Pregnancy Outcome”[MeSH])) OR (“Treatment Outcome”[MeSH] OR “Outcome and Process Assessment (Health Care)”[MeSH] OR “Fatal Outcome”[MeSH]) Limits: Humans, English | 369,350
#7 | Search #3 AND #6 Limits: Humans, English | 175
#17 | Search (“Patient Education as Topic”[MeSH] OR “Patient Education Handout “[Publication Type]) OR “Professional-Patient Relations”[MeSH]) OR “Office Visits”[MeSH] Limits: Humans, English | 109,582
#18 | Search #3 AND #17 Limits: Humans, English | 90
#26 | Search (“Costs and Cost Analysis”[MeSH] OR “Economics”[MeSH] OR “economics “[Subheading] OR “Cost-Benefit Analysis”[MeSH] OR “Cost Allocation”[MeSH] OR “Cost of Illness”[MeSH] OR “Cost Control”[MeSH] OR “Cost Sharing”[MeSH] OR “Cost Savings”[MeSH] OR “Health Care Costs”[MeSH] OR “Direct Service Costs”[MeSH] OR “Hospital Costs”[MeSH] OR “Employer Health Costs”[MeSH] OR “Drug Costs”[MeSH]) Limits: Humans, English | 257,114
#27 | Search #3 AND #26 Limits: Humans, English | 254
#28 | Search United States Limits: Humans, English | 606,881
#29 | Search #27 AND #28 Limits: Humans, English | 71
#33 | Search ((“Education”[MeSH] OR “education “[Subheading])) OR “Education, Professional”[MeSH] OR training Limits: Humans, English | 370,579
#34 | Search #3 AND #33 Limits: Humans, English | 1,013
#35 | Search #34 AND #28 Limits: Humans, English | 241
#41 | Search (“Randomized Controlled Trials as Topic”[MeSH] OR “Randomized Controlled Trial “[Publication Type]) OR “Single-Blind Method”[MeSH]) OR “Double-Blind Method”[MeSH]) OR “Random Allocation”[MeSH] Limits: Humans, English | 303,728
#42 | Search #3 AND #41 Limits: Humans, English | 165
#44 | Search control OR controlled Limits: Humans, English | 1,368,901
#45 | Search #3 AND #44 Limits: Humans, English | 908
#46 | Search #45 AND #28 Limits: Humans, English | 154
| Total unduplicated PubMed records | 640

Our initial searches in MEDLINE produced 640 unduplicated records. Searches in other databases (CINAHL, Cochrane, and Cochrane Clinical Trials Registry) yielded 169 new records (unduplicated across all databases) for a total of 809 records. We conducted update searches in all databases in November, 2008 and supplemented electronic searches with manual searches of reference lists. In addition, we received recommendations for studies of interest from the TEP and conducted a supplemental search on patient navigators after peer review. In all, we identified 1,076 unduplicated references from all searches (Table 3).

Table 3 Overall unduplicated results and sources of all searches

Original search of MEDLINE, Cochrane, Cochrane Clinical Trials Registry, CINAHL (April 2008) | 809
Update search of MEDLINE, Cochrane, Cochrane Clinical Trials Registry, CINAHL (November 2008) | 59
TEP recommended references | 10
Handsearches of reference lists | 173
Supplemental search (Patient Navigator) of MEDLINE, Cochrane, Cochrane Clinical Trials Registry, CINAHL | 25
TOTAL | 1,076

Figure 2 presents the yield and results from our searches, which we conducted from April through November 2008. Beginning with a yield of 1,076 articles, we retained 89 articles that we determined were relevant to address our KQs and met our inclusion/exclusion criteria (Figure 2). We reviewed titles and abstracts of the articles against the basic inclusion criteria above; we retained relevant articles and used them as appropriate in the discussion in Chapter 4.

Figure 2 Results of literature search

Article selection process. Once we had identified articles through the electronic database searches, review articles, and reference lists, we examined abstracts of articles to determine whether studies met our criteria. Each abstract was independently, dually reviewed for inclusion or exclusion, using an Abstract Review Form (Appendix B). If one reviewer concluded that the article should be included in the review, we retained it.

Of this entire group of 1,076 citations, 590 required full review. For the full article review, one team member read each article and decided whether it met our inclusion criteria, using a Full-Text Inclusion/Exclusion Form (Appendix B). Reasons for article exclusion are listed in Appendix D.

## Literature Synthesis

### Development of Evidence Tables and Data Abstraction Process

The team jointly developed the evidence tables. We designed the tables to provide sufficient information to enable readers to understand the studies and to determine their quality; we gave particular emphasis to essential information related to our KQs. We based the format of our evidence tables on successful designs that we have used for prior systematic reviews.

We trained abstractors by having them abstract several articles into evidence tables and then reconvening as a group to discuss the utility of the table design. The abstractors repeated this process through several iterations until they decided that the tables included the appropriate categories for gathering the information contained in the articles.

Four members of the team (Jennifer Kraschnewksi, Brett Nishikawa, Laura Morgan, and Patricia Thieda) shared the task of initially entering information into the evidence tables. Authors of individual sections reviewed the articles and edited all initial table entries for accuracy, completeness, and consistency. Abstractors reconciled all disagreements concerning the information reported in the evidence tables. The full research team met regularly during the article abstraction period and discussed global issues related to the data abstraction process.

The final evidence tables are presented in their entirety in Appendix C. Studies are presented in the evidence tables alphabetically by the last name of the first author. A list of abbreviations and acronyms used in the tables appears at the beginning of that appendix.

### Quality Rating of Individual Studies

Quality rating forms for RCTs have been validated and in use for several years; a similarly well-validated form for observational studies does not exist. RTI has been developing a form to rate observational studies.54 This form, which can be used to rate the quality of a variety of observational studies, was based on a review of more than 90 AHRQ systematic reviews that included observational studies; we supplemented this review with other key articles identifying domains and scales.55,56 We structured the resultant form largely on the basis of the domains and subdomains suggested by Deeks and colleagues;55 we then adapted it for use in this systematic review (Appendix B).

The form currently includes review of nine key domains for observational studies: background, sample selection, specification of exposure, specification of outcome, soundness of information, followup, analysis comparability, analysis of outcome, and interpretation. An additional domain for RCTs is the quality of randomization. We used these dimensions of quality to assess the overall quality of the study. We did not attempt to construct a quantitative scale for quality. Previous scales have been critiqued for their lack of inter-rater reliability. An additional concern is scales do not account for a single flaw that may substantially bias results, despite meeting standards for all other aspects of study quality. Each study was dually evaluated for quality; abstractors reconciled all disagreements.

### Strength of Available Evidence

We evaluated the strength of evidence based on the AHRQ Comparative Effectiveness Methods Guide.57 The strength of evidence for each outcome incorporates risk of bias, consistency, directness, precision, and the presence of other modifying factors. As described in Owens et al., the evaluation of risk of bias includes assessment of study design and aggregate quality of studies.57 We judged good quality studies with strong designs to result in evidence with low risk of bias. We graded evidence as consistent when effect sizes across studies were in the same direction and had a narrow range. When the evidence linked the interventions directly to health outcomes, we graded the evidence as being direct. We graded evidence as being precise when results had low degree of uncertainty. When considering the effect of confounders, we evaluated whether the degree of intensity of interventions in both arms could have explained the effects (or absence of effects); additionally we considered whether other sources of effect modification or confounding had been accounted for. We dually evaluated the overall strength of evidence for each outcome based on a qualitative assessment of strength of evidence for each domain and reconciled all disagreements. The levels of strength of evidence are shown in Table 4.

Table 4 Strength of evidence grades and definitions

Grade | Definition
High | High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit estimation of an effect.

### Applicability of the Evidence

We evaluated the applicability of the evidence based on a qualitative assessment of the population, intensity, or quality of treatment, choice of the comparator, outcomes, and timing of followup. We based our parameters for evaluation on guidance provided by AHRQ’s Comparative Effectiveness Methods Guide.58 Specifically, we consider whether enrolled populations differ from target populations and how this might affect risk of benefits or harms, whether studied interventions compare to those in routine use and how this might affect risk of benefits or harms, whether comparators reflect best alternative treatment and how this may influence treatment effect size, whether measured outcomes are known to reflect the most important clinical benefits and harms, and whether followup is sufficient to detect clinically important benefits.

## External Peer Review

AHRQ’s Scientific Resource Center requested review of this report from a wide array of outside experts. We received three external reviews and revised the report as appropriate.