# Introduction

## Background

### Health Disparities in the United States

The United States experienced remarkable improvements in public health and medical progress throughout much of the twentieth century. These advances, which have continued into the twenty-first century, have been accompanied by significant increases in medical spending. In 2003, total health care spending reached approximately $1.7 trillion, accounting for nearly 16 percent of the gross domestic product.1 An estimated 5.6 percent of total health care spending was on biomedical research, a proportion unmatched by any other country.2 Some experts note associations between US expenditures on biomedical research and major advances in pharmaceutical and medical device innovation2 and accompanying improvements in life expectancy.3

These improvements have not been accessible to all parts of US society. Substantial disparities in life expectancy,4 health, and health care persist.5–9 Repeated measures of disparities in quality of care and access to care since 2003 demonstrate, at best, only minor improvements.5–9 According to an Institute of Medicine (IOM) committee report, Unequal Treatment, these seemingly intractable differences cannot be explained by clinically appropriate care, differing needs of patients, or patient preferences.10 Moreover, access-related factors such as insurance status and income also cannot alone explain differences in quality of care or outcomes.10

Although many actors, including health care systems, insurers, health care providers, and patients, contribute to these disparities, bias, discrimination, and stereotyping during the clinical encounter also explain health care disparities.10 Recommendations of the IOM report, echoed by other publications,11,12 focus on reducing fragmentation in health care systems, improving awareness on the part of health care providers of these problems, strengthening culturally competent approaches to the delivery of health care, and increasing the diversity of the health care workforce.10

### Role of the Community Health Worker in Addressing Health Disparities

A core component in recommendations to address health disparities is the involvement of the community, specifically the involvement of community health workers (CHWs).10 Models of care using CHWs vary from making them an integral part of the care delivery team to involving them as community navigators, education providers, or outreach agents.13

A key variable along this spectrum is the extent to which CHWs operate within their own social networks. For example, CHW interventions using natural helpers rely on the specialized knowledge and expertise of CHWs working within their own social networks, whereas an outreach worker model may operate across social networks.14 The nomenclature for CHWs reflects this variation; it includes terms such as natural helpers, lay health advisors, patient navigators, and community health aides, among others. The disease conditions that CHWs help to address also reflect a wide spectrum, from AIDS prevention to smoking cessation, hypertension management to pediatric immunization, and asthma management to maternal and child care.

Common attributes across CHWs, regardless of nomenclature, health condition, or intervention include: (1) their role as health workers who share a relationship with their community (e.g., shared language, ethnicity, geography, race, or disease condition) and (2) the absence of professional training. The relationship that CHWs share with the community in which they work has long identified them as a natural bridge to the health care system.

Explanations for the anticipated outcomes of CHW interventions typically cite theories of individual behavior change.15–23 Theories of individual behavior change draw upon many ideas. Among them are the stages of change or the transtheoretical model (a framework for understanding motivational readiness to address problem behaviors24), social learning or social cognitive theory (an explanation of individual learning as operating through the observation of others within the context of behavioral, environmental, and personal factors25), and the health belief model (an explanation of individual health behaviors through attitudes and beliefs toward perceived susceptibility, severity, benefits, and barriers26).

Less frequently, authors acknowledge that these interventions also operate within the context of community change.27–29 According to Minkler and Wallerstein, collaborative models of community change range from community organizing (externally driven and motivated by community needs) to community building (internally generated and drawing upon community strengths) with variants in between.30 Several ideas help explain the drivers and mechanisms of community change: theories of social justice and human rights (the idea of health as a human right that CHWs can help to achieve in the interest of social justice28,31), collaborative empowerment (grantmakers, support organizations, local leaders, and individuals working together in a reciprocal manner32), and critical consciousness (the process of critical awareness by which community members become aware of their own agency and create spaces to work with others to bring about changes in individual and community health33,34).

CHW engagement is expected to diffuse community change to individuals; in addition, CHWs are postulated to reduce disparities through improving access to care, providing culturally competent health education, counseling, and sometimes rendering direct health services. Additionally, as trusted members of the community, CHWs may help to minimize barriers to care resulting from health beliefs and health values.10

### History of Community Health Workers

The history of CHWs supports the role that they continue today in providing services to marginalized populations. Perez and Martinez28 note that the earliest records of CHWs date back to a shortage of doctors in early 17th century Russia, when lay people, called “feldshers,” received training to provide basic medical care to military personnel.35 Later a similar model arose in China, where farmers with minimal medical training served as “barefoot doctors” to provide basic primary care, including vaccinations and treatment of minor illnesses, to rural underserved regions.28 Today, thousands of health programs employ CHWs worldwide for similar reasons.36

Internationally, a global shortage of medical workers has increased the call for these types of personnel. Significant health care workforce shortages are present in 57 countries, including countries in sub-Saharan Africa, Bangladesh, India, and Indonesia.37 Figures for the number of physicians per 100,000 people range from a low of 2 in Malawi to a high of 591 in Cuba; the number in the United States is 256.^37^ These figures represent overall physician proportions; the proportion of primary care physicians is far lower worldwide.

The AIDS epidemic in developing countries that already face a critical shortage of professional health care workers has strengthened the need to make greater use of CHWs. Task shifting allows CHWs to take on jobs that were previously performed by nurses; this phenomenon holds promise for rapidly filling the health care workforce deficit. One advantage of employing CHWs is the relatively short amount of training time they need, ranging from hours to weeks. This quick turnaround in training allows CHWs to be ready to provide services years before new nurses or doctors can complete their own training. Ultimately, the hope is that task shifting will improve access to primary care and, thus, serve to strengthen health care systems around the world.37

In the United States, despite the relatively high ratios of physicians to patients in this country, a significant percentage of the population remains underserved, particularly for primary care. An estimated one in five Americans are medically disenfranchised due to the shortage of primary care physicians, meaning they have inadequate or even no access to these physicians.38 The need to reduce health disparities among the underserved has led to an interest in CHW interventions within the United States. The 2007 Community Health Worker National Workforce Study suggests that the development of the CHW workforce in the United States occurred over four important time periods: early documentation (1966–1972), utilization of CHWs in special projects (1973–1989), state and federal initiatives (1990–1998), and public policy options (1999–2007).13 Few references to CHW interventions appear in the literature before the mid-1960s.

During the period of early documentation (1966–1972), CHWs were used to address problems of the poor rather than in specific health improvement models. The New York City Health Department first documented CHW use in a 1960s-era tuberculosis program that involved “neighborhood health aides.”39 One early effectiveness study on CHWs (published in 1970) consisted of a CHW intervention with nurses and physicians to improve compliance in treating pediatric infections.40

Public and private funding of projects involving CHWs continued to grow from 1973 to 1989, in turn prompting more publications.13 Further attention was brought to CHWs as a result of a World Health Organization (WHO) declaration in 1978, proposing the development of national CHW programs as important for promoting primary health care.41 Another significant step for dissemination of CHW programs occurred when the “Resource Mothers” curriculum, prepared for the Virginia Task Force on Infant Mortality during the 1980s, became one of the early CHW curricula distributed nationally.42

From 1990 to 1998, several state and federal bills proposed CHW interventions; none, however, was enacted. Despite this lack of legislative support, training centers dedicated to CHWs opened in Boston43 and San Francisco.44 Support remained high for the promise of CHW interventions with the expectation that the widespread incorporation of CHWs into the health delivery system would offer opportunities to improve the delivery of preventive and primary health care in the United States.45

The state of Texas passed the first legislation addressing the CHW workforce in 1999, starting the public policy options period (1999–2006).13,46 During this time, several associations called for expansion of CHW roles and projects, including the National Rural Health Association, the American Association of Diabetes Educators, and the American Public Health Association. As noted earlier, the 2003 IOM report also made recommendations regarding the role of CHWs in addressing health care disparities.10 Finally, during this same period the first national legislation on CHWs was passed: The Patient Navigator Outreach and Chronic Disease Prevention Act of 2005. Additionally, the state of Minnesota passed legislation allowing for Medicaid coverage of CHW services in December of 2007.^47^

In 2000, an estimated 86,000 CHWs were supporting American communities.13 The number of CHWs has continued to grow since then to an estimated 121,000 CHWs in 2005, representing a 41 percent increase from 2000.^13^

## Key Questions and Analytic Framework

### Key Questions

Numerous recent reviews have examined the effectiveness of CHWs, but their scope has often been limited to specific disease conditions,48,49 subpopulations,50,51 or study designs.52,53 The Agency for Healthcare Research and Quality (AHRQ) commissioned the RTI International–University of North Carolina Evidence-based Practice Center (RTI-UNC EPC) to conduct a systematic review on outcomes of CHW interventions. The nominator for this work was the Minnesota Department of Human Services (MDHS).

The EPC received and revised key questions (KQs) after discussions with internal technical staff, AHRQ staff, MDHS staff, and our Technical Expert Panel (TEP, see below). The final KQs are as follows:

- KQ 1. How do community health workers interact with participants? Specifically, what is the place of service, type of service, type of educational materials used, duration of interaction with participants, and length of followup?
- KQ 2. What is the impact of community health workers on outcomes, particularly knowledge, behavior, satisfaction, health outcomes, and health care utilization?
- KQ 3. What is known about the cost-effectiveness of community health workers for improving health outcomes?
- KQ 4a. What are characteristics of training for community health workers in the outpatient setting?
- KQ 4b. Are particular training characteristics associated with improved outcomes for patients?

### Analytic Framework for Outcomes of Community Health Worker Interventions

Based on our discussion with TEP members, we used the following operational definition of CHWs: A CHW:

- Performs health-related tasks to create a bridge between community members, especially hard-to-reach populations, and the health care system (i.e., performs tasks extending beyond peer counseling or peer support alone).
- Has health training associated with the intervention; training is shorter than that of a professional worker (i.e., training does not form part of a tertiary education certificate).
- Is recognized (or can be identified) as a member of the community in which he or she works, defined by but not limited to, geographic location, race or ethnicity, and exposure or disease status.

As reflected in Figure 1, KQ 1 and KQ 4a are descriptive questions. The information obtained through KQ 1 will inform KQ 2. KQ 3 evaluates cost information for the subset of evidence identified in KQ 1 as effective. The heterogeneity of health conditions, CHW intervention types, and comparators will be explicitly addressed in all KQs.

Figure 1 Outcomes of community health worker interventions: conceptual framework

## Production of This Evidence Report

### Organization

Chapter 2 describes our methods, including our search strategies and inclusion/exclusion criteria; we also document our approach to grading the quality of articles and rating the strength of evidence. In Chapter 3, we report the results of literature searches and synthesis of retained articles for KQs 1, 2, 3, and 4. Chapter 4 presents our conclusions and offers our recommendations for future research.

References and included studies follow Chapter 4. Appendixes include a detailed description of our search strings (Appendix A), data collection forms (Appendix B), detailed evidence tables (Appendix C), excluded studies (Appendix D), and acknowledgments (Appendix E).

### Technical Expert Panel (TEP)

In designing the study questions and methodology at the outset of this report, we consulted several technical and content experts, seeking broad expertise and perspectives. We identified seven technical experts to provide assistance throughout the project (Appendix E); two were employed by the Minnesota Department of Human Services (the nominator for this topic). The TEP contributed to AHRQ’s broader goals of (1) creating and maintaining science partnerships as well as public-private partnerships and (2) meeting the needs of an array of potential customers and users of its products. Thus, the TEP was both an additional resource and a sounding board during the project.

Divergent and conflicting opinions are common; we perceive them as healthy scientific discourse that contributes to a thoughtful, relevant systematic review. Nonetheless, in the end, study questions, design, and/or methodologic approaches do not necessarily represent the views of individual technical and content experts.

To ensure robust, scientifically relevant work, we called on the TEP to provide reactions to work in progress and advice on substantive issues or possibly overlooked areas of research. Specifically, TEP members participated in conference calls and discussions through e-mail to:

- refine the analytic framework and KQs at the beginning of the project;
- discuss the preliminary assessment of the literature, including inclusion/exclusion criteria; and
- provide input on the information and categories included in evidence tables.

Because of their extensive knowledge of the literature, including numerous articles authored by TEP members themselves, and their active involvement in the field, we also asked TEP members to participate in the external peer review of the draft report.

## Uses of This Report

We anticipate that this report will be useful to primary care and public health practitioners; community health workers; national, state, and local health policy makers; Medicaid and other public and private insurers; and community-based researchers. As noted above, we will explicitly consider CHW effectiveness by clinical concern; specialists in these areas may also find this report to be of use in designing and allocating resources for future CHW interventions.