# Acknowledgments

This study was supported by Contract 290200710056I from the Agency for Healthcare Research and Quality (AHRQ), Task No.3, Work Assignment 1. We acknowledge the continuing support of Beth Collins Sharp, Ph.D., R.N. Acting Director of the AHRQ Evidence-Based Practice Center (EPC) Program and the AHRQ Task Order Officer for this project.

The investigators deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at RTI International and the University of North Carolina (UNC). From UNC, we thank EPC Co-Director, Timothy S. Carey, M.D., M.P.H.; EPC Literature Search Specialist, B. Lynn Whitener, Ph.D. We express our gratitude to Linda Lux, M.P.A., EPC Coordinator, Jennifer Drolet, EPC Editor, and Loraine Monroe, EPC publication specialist at RTI International.

## Technical Expert Panel

We extend our appreciation to the members of our Technical Expert Panel (TEP), who provided advice and input during our research process. The RTI-UNC EPC team solicited the views of TEP members from the beginning of the project. TEP members also provided insights into and reactions to work in progress and advice on substantive issues or possibly overlooked areas of research. TEP members participated in refining the analytic framework and key questions and discussing the preliminary assessment of the literature, including inclusion/exclusion criteria, and also provided input on the information and categories, including evidence tables. The TEP was both a substantive resource and a “sounding board” throughout the study. It was also the body from which expertise was formally sought at several junctions.

TEP Member | Affiliation
Andrea Cherrington, M.D. | University of Alabama at Birmingham Birmingham, AL
Michael Gibbons, M.D., M.P.H. | Johns Hopkins Bloomberg School of Public Health Baltimore, MD
Susan Norris, M.D. | Oregon Health & Science University Portland, OR
Barbara Israel, Ph.D. | University of Michigan Ann Arbor, MI
James Krieger, M.D., M.P.H. | University of Washington, Seattle Seattle, WA
Ross Owen, M.P.A. | Minnesota Department of Human Services St. Paul, MN
Mary Pohl, M.D. | Minnesota Department of Human Services St. Paul, MN

## Peer Review

Peer reviewers read and provided feedback on a draft version of the report. We revised the report as appropriate in response to their suggestions.

Peer Reviewers | Affiliation
Ross Owen, M.P.A. | Minnesota Department of Human Services St. Paul, MN
Lenore Coover, R.N. | Private consultant
Sally Findley, Ph.D. | Mailman School of Public Health Columbia University 60 Haven New York, NY 10032