# Evidence Tables

List of Abbreviations
AA: African American
AIDS: Acquired immune deficiency syndrome
b/c: because
BF: breastfeeding
BMI: body mass index
BP: blood pressure
BSN: bachelor of science - Nursing
BW: body weight
CAD: Coronary artery disease
CBC: community based care
CD: cannot determine
CES: Community environmental specialists
CES-D: Center for Epidemiologic Studies Depression Scale
CG: control group
CHD: coronary heart disease
CHO: Carbohydrates
CHW(s): community health worker(s)
CPEP: Child Parent Enrichment Program
DR: Doctor
DSM-III-R: Diagnostic and Statistical Manual of Mental Disorders, 3^rd^ edition, revised
EAG: Enhanced Anticipatory Guidance
EG: experimental group
EPC: evidence-based practice center
EPC: “enhanced” primary care
ER: emergency room
ETS: Environmental tobacco smoke
FPL: federal poverty level
FTT: Failure to thrive
g: gram
GED: general education degree
GHC: Group Health Cooperative of Puget Sound
gm: gram
h: hour
HbA1c: Glycosylated (or glycated) hemoglobin
HBP: high blood pressure
HIV: Human immunodeficiency virus
HMO: Health Maintenance Organization
HS: high school
HSP: Hawaii’s Health Start Program
ht: height
HTN: hypertension
hx: history
ICD: International Classification of Diseases
IHDP: Infant Health and Development Program
IL: Illinois
ITT: intent to treat
JNC-VI: Sixth Report of Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure
kcal: kilocalorie
LBW: low birth weight
LDL: Low-density lipoprotein
LHA: Lay Health Advisor
MD: medical doctor; Maryland
mg/dl: milligrams/deciliter
MI: Michigan
min: minute
mmol/L: millimoles/liter
mo: month
N: number
NA: not applicable
NCM: nurse case manager
NDS: Nutrition Data System
NNT: number needed to treat
NP: nurse practitioner
NR: not reported
NS: not significant
NW: northwest
NY: New York
NYC: New York City
PCP: primary care physician
PI: principal investigator
PKU: phenylketonuria
PSI: Psychiatric Symptom Index
RCT: randomized controlled trials
REACH: Resources, Education and Care in Home
RIA: radioimmunoassay
RN: registered nurse
SBP: systolic blood pressure
SD: standard deviation
SE: standard error
SLE: stressful life events
TPV: tailored print and video
UC: usual care
VLBW: very low birth weight
WATCH: Wellness for African Americans Through Churches Project
WIC: Women, Infants, and Children
wk: week
y: year
y/o: years old
YMCA: Young Men’s Christian Association
yr: year

Evidence Table C-1 Key Questions 1, 2, and 3

Study Characteristics Setting | Number (N) Inclusion/Exclusion Groups | Community Health Worker | Baseline Characteristics Recruiting and Retention | Knowledge, Attitude, and Behavior Quality of Life | Health Outcomes Healthcare Utilization | Costs (Economics) Additional Outcomes
Author Year Andersen et al., 2000 Trial Name Community Trial of Mammography Promotion Objective or Aim To learn how best to increase use of screening among women aged 50 to 80 Geography 40 communities in predominantly rural Washington state, selected by zipcodes corresponding to towns or clusters of towns Organization Community or telephone Type of Community Rural neighborhoods Study Design RCT of communities Start Date NR Duration 2 years | Eligible (N) 10,967 at baseline 8,907 at followup Enrolled (N) 10,967 Randomized (N) 14,080 Completers (N) 6,685 Withdrawals or Dropouts (N) 2,222 of N eligible at followup Health Condition of Interest Mammography Inclusion Criteria Women age 50 to 80 living in one of 40 communities Exclusion Criteria History of breast cancer Groups G1: Control G2: Community activities G3: Individual counseling G4: Both Interventions G1: Control, no intervention reported G2: Community activities - developing social norms G3: Individual counseling - telephone G4: Community activities and individual couseling Group (N) G1: 1,688 G2: 1,630 G3: 1,650 G4: 1,717 | Title of CHW Volunteer Paid or Volunteer Volunteer Relationship with Community Shared community CHW (N) NR Supervision of CHW Non-clinician- field research coordinators Prior Training NR Type of Service Barrier-specific telephone counseling to promote screening Type of Educational Materials Used NR Duration of Interaction with Clients One interaction (time of interaction NR) Length of Follow-up 2 years | Age (mean) NR Sex (% female) 100 Race (%) 97% white Other NR Role of CHW in Recruiting and Retention None Recruitment Rates NA Retention Rates NA | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: NR Healthcare Utilization: Measure 1 Increase in mammography rates (self-reported) Results No significant differences between intervention groups and control; no significant differences for individual counseling or combined individual couseling and communitities activities, but increased mammography use by regular users between baseline and followup for community activities arm by 2.9% (P = 0.01). Measure 2 Increase in mammography rates (self-reported) Results Among under-users at baseline, intervention more effective than control in increasing mammography rates amon women with in communities without a female physician (10% to 16%; P < 0.05), and among women with no health insurance (10% to 23%; P ≤ 0.05); NS effect for community attitudes on mammography, age, time taken to get a medical appointment, financial comfort, mammography facility in community, income, education, proportion of Hispanic population, urban/rural, size of community, and employment status among regular users, intervention was more effective than control in preventing relapse among women who needed > 2 hours to get a medical appointment. NS effect for community attitudes on mammography, age, use of mammography in community, female MD, financial comfort, mammography facility in community, income, education, proportion of Hispanic population, urban/rural, size of community, and employment status | Costs (Economics): NR Explanation of Overall Outcomes NR Quality Rating Good
Author Year Auslander et al., 2002; Williams et al., 2001 Trial Name Eat Well Live Well Nutrition Program Objective or Aim A culturally specific, peer-led dietary change program designed to reduce risk of type 2 diabetes in low-income African-American women. Geography Large Midwestern city in Missouri Organization Targeted neighborhoods Type of Community Race, Neighborhood Study Design RCT Start Date NR Duration 3 months | Eligible (N) NR Enrolled (N) NR Randomized (N) NR Completers (N) 294 Withdrawals or Dropouts (N) 104 Health Condition of Interest Diabetes Prevention Inclusion Criteria African-American women ages 25–55 years and living in neighborhoods Exclusion Criteria Pregnancy, diabetes, BMI < 27 Groups G1: Treatment G2: Control Interventions G1: Six group sessions (approximately six to eight participants per group) and six individual sessions targeting stages of change to tailor dietary pattern with a peer educator, meeting weekly over a 3-month period; duration of each session 45–90 minutes G2: Control - a book Group (N) G1: Treatment 138 G2: Control 156 | Title of CHW Peer educators Paid or Volunteer NR Relationship with Community African-American women from target community with no background in nutrition or education, were recruited by lead agency to deliver intervention. CHW (N) 3 Supervision of CHW Weekly supervision during implementation phases, including meeting with educators, research dietitian, project coordinator and research assistants Prior Training No background in nutrition or education Type of Service Counseling Type of Educational Materials Used Program Manual Duration of Interaction with Clients 3 months Length of Follow-up 3 months | Age (mean) G1: 41.2 G2: 40.2 Sex (% female) 1 Race (%) African-American Other NR Role of CHW in Recruiting and Retention NR Recruitment Rates NR Retention Rates NR | Knowledge, Attitude, and Behavior: Measure 1 Knowledge of Label Reading Questionnaire (Unvalidated) –baseline/6 months Results G2: 5.4/5.7, G1: 5.5/6.3 (P > 0.0001) Measure 2 Readiness to change dietary patterns - no Results Overall, participants in treatment group reported a greater readiness to change their dietary patterns than those in control group at posttest assessment. Quality of Life: NR | Health Outcomes: Measure 1 Weight, BMI Results No significant group differences Measure 2 FFQ - Validated Results Intervention was effective in reducing fat intake, as measured by percent of calories from total fat (baseline/6 months): G2: 36.0/34.5, G1: 35.9/32.3, P < 0.05 Healthcare Utilization: NR | Costs (Economics): NR Explanation of Overall Outcomes NR Quality Rating Fair
Author Year Barnes et al., 1999 Trial Name NR Objective or Aim To assess effectiveness of a volunteer driven outreach program on immunization rates in children younger than 2 years. Geography NW Manhatten, NY Organization Organizational: Patients of 1 of 2 ambulatory pediatric clinics of a major medical center Type of Community Low-income children who are part of a large, highly mobile immigrant community originating from DR Study Design RCT Start Date 1993 Duration 6 months | Eligible (N) 434 Enrolled (N) 163 Randomized (N) 434 Completers (N) 140 Withdrawals or Dropouts (N) 23 Health Condition of Interest Immunizations Inclusion Criteria • Younger than 2 years residing in NW Manhattan • No-shows for a scheduled appointment in pediatric clinic, and • Overdue for a vaccine. Exclusion Criteria NR Groups G1: Intervention G2: Control Interventions G1: Basic immunization education and referral. During subsequent contacts (home visits or telephone calls) throughout remainder of follow-up, families were reminded of upcoming vaccinations and were recontacted to ensure that requisite vaccines were received. If a family required support or assistance to obtain immunization services G2: Informed of their child’s immunization status at enrollment visit by control group interviewer and were instructed to reschedule missed appointment. Group (N) G1: 71 G2: 84 | Title of CHW Community volunteers Paid or Volunteer Volunteer Relationship with Community NR- community volunteers CHW (N) NR Supervision of CHW Organized by coordinator from local branch of larger international charitable organization Prior Training NR Type of Service Unspecified # of home visits and phone calls Type of Educational Materials Used NR Duration of Interaction with Clients Unspecified # of calls and visits over 6 months (time per session NR) Length of Follow-up Maximum of 6 months | Age (mean) G1: 9.5 months G2: 9.4 months Sex (% female) G1: 50 G2: 40 Race (%) G1: 87% Hispanic G2: 85% Hispanic Other Primary language of caregiver -spanish G1: 66 G2: 75% Role of CHW in Recruiting and Retention NR Recruitment Rates NR Retention Rates NR | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: NR Healthcare Utilization: Measure 1 Late for immunization Results G1: 18% G2: 38% P < 0.05 Measure 2 Up to date on immunizations Results G1: 75% G2: 54% P = 0.03 | Costs (Economics): NR Explanation of Overall Outcomes NR Quality Rating Fair
Author Year Barnes-Boyd et al., 2001 Trial Name REACH-Futures Objective or Aim NR Geography Chicago Organization Inner city community clinic Type of Community Mostly African- American; impoverished; low employment and literacy, high infant and child morbidity and mortality, poor maternal outcomes, high incidence early unplanned pregnancies and childhood injuries Study Design Cohort with historic control Start Date 1986 Duration 8 years | Eligible (N) 1,922 Enrolled (N) 1,922 Randomized (N) NA Completers (N) NA Withdrawals or Dropouts (N) 0 Health Condition of Interest Infant health Inclusion Criteria All recipients: • below 150% of poverty line • lived in inner-city communities Exclusion Criteria NA Groups G1: REACH-Futures CHW+nurse G2: REACH nurse-only historic control Interventions • Home visits-family focused care plan • Support model problem-solving skills • Promote self-development of mother • Provide instruction in infant care •Transportation • Find community resources for childhood immunizations Group (N) G1: 666 G2: 1256 | Title of CHW Maternal-Child Health Advocate Paid or Volunteer Paid Relationship with Community Within community CHW (N) 10 Supervision of CHW Teamed with nurses (at least BSN) Prior Training • Minimum HS or GED • Experience in community service Type of Service home visits Type of Educational Materials Used Direct instruction Duration of Interaction with Clients 12 monthly visits by CHW alone, teamed with nurses for one prenatal visit and at 1, 6 and 12 months; duration per visit NR Length of Follow-up 12 months | Age (mean) G1: 51% < 20 y/o G2: 36% < 20 y/o Sex (% female) 100 Race (%) G1: 85% African-American G2: 80% African-American Other G1: 56% primiparous G2: 41% G1: 53% < HS education G2: 36% G1: 94% BW > 2500gm G2: 93% Role of CHW in Recruiting and Retention NR Recruitment Rates NR Retention Rates G1: 2 mo 86%, 11 mo 56% G2: 2 mo 75%, 11 mo 58% | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: Measure 1 Extrapolated infant mortality rate (n too small) Results G1: 3.0 G2: 4.7 (not significant) Measure 2 Presence of health problems Results Neonatal G1: 27% G2: 25% Postneonatal G1: 27% G2: 25% (neither significant) Measure 3 % fully immunized at 12 months Results G1: 77% G2: 63% (P < 0.001) Healthcare Utilization: NR | Costs (Economics): NR Explanation of Overall Outcomes CHW+nurse home visits resulted in higher immunization status than nurse-only visits; no difference in health problems or mortality Quality Rating Poor
Author Year Barth et al., 1988 Trial Name CPEP Objective or Aim Preventing child abuse Geography California/Contra Costa County Organization Social Type of Community At risk Study Design RCT Start Date NR Duration 6 months | Eligible (N) 95 referred Enrolled (N) 65 enrolled Randomized (N) 65 Completers (N) 50 G1: 24 G2: 26 Withdrawals or Dropouts (N) G1: 5 G2: 10 Health Condition of Interest Child abuse Inclusion Criteria Referred to CPEP, by public health, education, or social service professionals Exclusion Criteria NA Groups G1: Intervention G2: Control Interventions G1: CPEP services involved six months of home visiting by paraprofessional women and linkage to other formal and informal community resources. Group (N) G1: 24 G2: 26 | Title of CHW Parenting Consultants Paid or Volunteer NR Relationship with Community Members of community CHW (N) 8 Supervision of CHW Group Supervision Prior Training 100 hours Type of Service Task centered approach Type of Educational Materials Used NR Duration of Interaction with Clients ≈2 visits per month, ≈ 4 hours per session, over 6 months Length of Follow-up 6 months | Age (mean) G1: 21.75 G2: 23.04 Sex (% female) 100 Race (%) • 43% white • 27% were Latino (primarily Chicano) • 20% black • 6% were Asian (primarily South East Asian refugees) • 4% Native American Other Role of CHW in Recruiting and Retention NR Recruitment Rates NR Retention Rates NR | Knowledge, Attitude, and Behavior: NR Quality of Life: Measure 1 Child Abuse Potential Inventory Results G1: pre/post means 116.33/88.54 G2: pre/post means 103.50/92.44 No significant difference between posttests | Health Outcomes: NR Healthcare Utilization: NR | Costs (Economics): NR Explanation of Overall Outcomes Overall no differences in outcomes, though clients appreciated services Quality Rating Poor
Author Year Barth, 1991 Trial Name CPEP Objective or Aim Prevent child abuse Geography Contra Costa County, California Organization Organizational/Community Type of Community At risk for chid abuse Study Design RCT Start Date NR Duration 6 months | Eligible (N) 313 referred Enrolled (N) 240 Randomized (N) 240 Completers (N) 61% (191) Withdrawals or Dropouts (N) 39% (49) Health Condition of Interest Child abuse Inclusion Criteria Referred to CPEP by public health, education, or social service professionals Exclusion Criteria NA Groups G1: Intervention G2: Control Interventions G1: Intervention G2: Control Group (N) G1: 97 G2: 94 (Completers - article indicates 240 were initially randomized but only 191 completed posttest) | Title of CHW Parenting Consultants Paid or Volunteer NR Relationship with Community Members of community CHW (N) 8 Supervision of CHW Group supervision Prior Training NR Type of Service<br>• Task centered approach • Home visits • Links to community resources Type of Educational Materials Used NR Duration of Interaction with Clients On average 11 visits (range 5–20) over 6 months (time per session not reported but ≈ 4 hours implied) Length of Follow-up Mean 3 years (range 2–5) | Age (mean) G1: 23.25 G2: 23.75 Sex (% female) 100 Race (%)<br>• White: 45% • Latin (primarily Chicano): 31% • Black: 17% • Other: 7% Other Role of CHW in Recruiting and Retention NR Recruitment Rates NR Retention Rates NR | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: Measure 1 Reported child abuse Results No differences in increase between groups Healthcare Utilization: NR | Costs (Economics): NR Explanation of Overall Outcomes Overall no differences in outcomes, though clients appreciated services Quality Rating Poor
Author Year Batts et al., 2001; Garyet al., 2003; Vetter, et al., 2004; Gary et al., 2005; Gary et al., 2000 Trial Name Project Sugar Objective or Aim To determine diabetes care priorities and needs in a group of urban African-American adults with type 2 diabetes; To determine prevalence of depressive symptoms and relationship between depressive symptoms and metabolic control . Geography East Baltimore, MD Organization 2 primary care clinics Type of Community African-American adults with type 2 diabetes Study Design RCT Start Date 1994 Duration 2 years | Eligible (N) 822 Enrolled (N) 332 Randomized (N) 186 Completers (N) 183 Withdrawals or Dropouts (N) 3 Health Condition of Interest • Diabetes Mellitus, type 2 • Depression Inclusion Criteria Eligibility criteria included following: • Age 35–75 years • African-American ancestry • Residence in East Baltimore • Presence of type 2 diabetes • Absence of comorbid conditions limiting probable life span to 4 years (e.g., cancer, AIDS) • Attendance at either of 2 Johns Hopkins–affiliated primary care clinics • No indication of end-stage complications of diabetes (e.g., kidney dialysis or transplant, blindness, or lower- extremity amputation) Exclusion Criteria • Comorbid conditions limiting probable life span < 4 years • Indication of end-stage complications of diabetes (dialysis or t+R2ransplant, blindness or lower extremity amputation) Groups G1: usual care G2: nurse care manager G3: CHW G4: NCM + CHW Interventions G1: continued on-going care from their own health professionals + quarterly newsletter containing info on diabetes- related health topics and trial communication G2: NCM intervention: NCM was RN + certified diabetes educator, interventions were 45 min face-to-face clinic visits and/or phone contacts, direct patient care, management, education, counseling, follow-up, referral and physician feedback - goal was 3 visits/yr G3: CHW interventions were 45–60 min face-to-face home visits and/or phone contacts, no direct implementation of therapeutic strategieis but facilitated preventibe care by offering to schedule appointments + provide education, 3 visits/yr G4: combined NCM + CHW − three visits/year with each Group (N) G1: 34 G2: 38 G3: 41 G4: 36 | Title of CHW Members of community of interest trained to perform non-medical case management tasks Paid or Volunteer NR Relationship with Community • Local hs graduate enrolled in college part- time • No formal training in health care prior to study CHW (N) 1 Supervision of CHW NR Prior Training None Type of Service • Home visits to provide education • Mobilize social support for adults with diabetes mellitus Type of Educational Materials Used NR Duration of Interaction with Clients 3 visits (45–60 minutes each) per year over 2 years (+ additional contacts as needed) Length of Follow-up 2 years | Age (mean) 59 Sex (% female) 75 Race (%) 100% AA Other • 50% had an income of $7,500 • Participants had diabetes an average of 9 years • 91% on medication (46% used insulin, 45% used an oral agent) Role of CHW in Recruiting and Retention NR Recruitment Rates NR Retention Rates NR | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: Measure 1 LDL Results G1: −16.7± 5.5 mg/dl G2: +6 (approx) (P<0.05 for within-group change from baseline) G3: +6 (approx.) G4: + 4 (approx.) (P<0.05 for within-group change from baseline) Measure 2 SBP Results G1: ref G2: +6 (approx.) (P<0.05 for within-group change from baseline) G3: −4 (approx) G4: −2 (approx). Measure 3 hga1c Results G1: ref G2: −0.31 ± 0.49% G3: −0.30 ± 0.48% G4: 0.8 ± 0.52% Measure 4 Dietary risk scores Results G1: ref G2: −2.4± 1.99 G3: −3.45 ± 1.87 G4: −2.13 ± 1.92 Healthcare Utilization: NR | Costs (Economics): NR Explanation of Overall Outcomes NR Quality Rating Good
Author Year Becker et al., 2005; Cene et al., 2008 Trial Name NR Objective or Aim Determine relative effectiveness of alternative model of community-based care provided in black community compared with “enhanced” primary care Geography Baltimore, MD Organization Identified from Baltimore Hospitals Type of Community Blacks Study Design RCT Start Date NR Duration 1 year | Eligible (N) NR Enrolled (N) NR Randomized (N) 364 siblings (194 families) Completers (N) 267 Withdrawals or Dropouts (N) 97 Health Condition of Interest Cardiovascular disease prevention Inclusion Criteria • Sibling of black < 60 years hospitalized for a CHD event at one of 10 Baltimore hospitals • Aged 30–59 • No known history of CAD • No chronic glucocorticosteroid therapy • No autoimmune disease • No cancer • No immediate life-threatening comorbidity Exclusion Criteria See prior Groups G1: EPC G2: CBC Interventions G1: EPC- received risk-specific materials (same as intervention group), PCP received results and recommendations, sent info on YMCA program, etc. G2: CBC - received care in 1 nonclinical site in community from a NP and CHW. CHW provided dietary counseling, smoking cessation, and exercise counseling lasting 30 minutes. Group (N) G1: 168 G2: 196 | Title of CHW CHW Paid or Volunteer NR Relationship with Community “Culturally sensitive navigator” CHW (N) 1? Supervision of CHW NR Prior Training NR Type of Service Counseling for adults with risk factors for cardiovascular disease, face-to-face, phone calls Type of Educational Materials Used Written, culturally sensitive Duration of Interaction with Clients Multiple (# unspecified) 30 minute sessions over 1 year Length of Follow-up 1 year | Age (mean) G1: 47.9 G2: 47.6 Sex (% female) G1: 66 G2: 61 Race (%) African American:100% Other Role of CHW in Recruiting and Retention NA Recruitment Rates NA Retention Rates NA | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: Measure 1 Smoking Cessation (self-report) Results G1: 7% reduction G2: 16.2% reduction (P < 0.001) Measure 2 BP Results Measure 3 LDL (mmol/L) Results G1: 3.38+−1 G2: 3.06+−1 (P < 0.0001) Healthcare Utilization: NR | Costs (Economics): NR Explanation of Overall Outcomes NR Quality Rating Fair
Author Year Beckham et al., 2008 Trial Name NR Objective or Aim Effectiveness of CHWs on diabetes management among a population with primarily Native Hawaiian and Samoan ethnic minority participants with HbA1c greater than 10% Geography Hawaii Organization Organizational Type of Community Underserved diabetics Study Design Prospective cohort Start Date 2002 Duration Up to a year | Eligible (N) 175 Enrolled (N) 116 Randomized (N) NA Completers (N) 80 Withdrawals or Dropouts (N) NA Health Condition of Interest Diabetes Inclusion Criteria Patients with HBa1C > 10 Exclusion Criteria Refusal to participate (these became control group) Groups G1: Intervention G2: UC Interventions G1: diabetes case management by CHW, including home visits; based on needs of patients, CHWs collaborate with rest of multidisciplinary team to determine high-priority learning areas and to develop an intervention plan to implement during subsequent visits, plan included a blood regimen and target levels, diet plan, exercise plan, medication schedule, insulin injetion plan, and preventive health/health mainteance plan G2: UC Group (N) G1: 80 G2: 36 | Title of CHW Community health worker Paid or Volunteer Paid Relationship with Community Ethnicity and language CHW (N) 3 Supervision of CHW CHWs met with Medical Director and Preventive Health Department Director once every 2 weeks for in- service training and case conferences for duration of project. Prior Training 6 months of study at community college Type of Service Based on needs of patient - CHWs would collaborate with rest of multidisciplinary team to determine high-priority learning areas and to develop an intervention plan to implement during subsequent visits. Each plan included a blood glucose self-monitoring regimen and target levels, diet plan, exercise plan, medication schedule, insulin injection plan, and preventive health/health maintenance plan. Type of Educational Materials Used NR Duration of Interaction with Clients Up to a year - number of CHW visits per participant averaged 4.24 (range 5 1–15 visits), with each visit averaging 1 to 1.5 hours. Length of Follow-up 1 year | Age (mean) G1: 51.8 G2: 46.6 Sex (% female) G1: 55 G2: 50 Race (%) G1: Hawaiian 51.3% Samoan 12.5% Filipino10% Caucasian 16.2% Tongan 2.5% Other 7.5% G2: Hawaiian 55.6% Samoan 11.1% Filipino 8.3% Caucasian 11.1% Tongan 2.8% Other 11.1% Other Baseline HbA1c (%) G1: 11.0 (6 .8) G2: 10.8 (6 (%) Role of CHW in Recruiting and Retention NR Recruitment Rates NR Retention Rates NR | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: Measure 1 Post intervention period HbA1c Results G1: 8.8 6 (1.7) G2: 10.4 (6 1.3) P < 0.0001 (Note on P value: investigators did not report one comparing groups, RTI researchers calculated it using data in article Measure 2 Decrease in HbA1C Results G1: 2.2 (SD 1.8) G2: 0.2 (SD 1.5); P < 0.01 compared to baseline Healthcare Utilization: NR | Costs (Economics): NR Explanation of Overall Outcomes NR Quality Rating Fair
Author Year Blacket al., 1995; Hutcheson, et al., 1997 Trial Name NR Objective or Aim Evaluate efficacy of family-focused, home-based intervention on growth and development of children with nonorganic FTT Geography Baltimore, MD Organization Recruited from urban pediatric clinics serving low income families Type of Community Low-income, urban Study Design RCT Start Date NR Duration 1 year | Eligible (N) approx 163 Enrolled (N) 130 Randomized (N) 130 Completers (N) 706: 116 ( to end of intervention) 1445: 74 (to 4 y/o) Withdrawals or Dropouts (N) 706: 14 1445: 56 Health Condition of Interest Nonorganic failure to thrive Inclusion Criteria • < 25 mo • Wt for age < 5th percentile • EGA 36+ wk • Birth weight appropriate for gestational age • Wt for ht < 10th percentile Exclusion Criteria • No congenital disorders • No chronic illness • No developmental disabilities Groups G1: home intervention G2: clinic-only Interventions G1: CHW home visit weekly × 1 year w/community health nurse supervision G2: clinic-based multidisciplinary services Group (N) G1: 64 G2: 66 | Title of CHW Lay home visitor Paid or Volunteer Paid Relationship with Community Knowledge of community Familiarity with culture CHW (N) 3 part-time Supervision of CHW Community health nurse, frequency NR Prior Training Experience with children and families Type of Service • Home visits to develop individualized family service plan with specific goals • Support mother’s needs • Promote maternal-child relationship Type of Educational Materials Used Hawaii Early Learning Program was used as curriculum guide; handouts, developmental assessment toys, personalized notebooks Duration of Interaction with Clients Weekly visits (≈ 1 hour per visit) for 1 year Length of Follow-up 18 months | Age (mean) G1: younger 7.8 mo (SD 2.8); older 17.1 mo (3.7) G2: younger 6.6 (3.6); older 17.9 (4.3) Sex (% female) G1: younger 50%, older 44% G2: younger 45%, older 38% Race (%) African American – G1: younger 84%, older 91% G2: younger 85%, older 97% Other Mean BW G1: younger 2881 gm (400), older 2868 (385) G2: younger 3010 (524), older 2881 (432) Prior FTT hospitalization G1: younger 6%, older 0 G2: younger 10%, older 3% Role of CHW in Recruiting and Retention NR Recruitment Rates 80% overall Retention Rates 706: G1: 89% G2: 89% 1,445: G1: 65% G2: 68% | Knowledge, Attitude, and Behavior: NR Quality of Life: Measure 1 Home environment (validated: Home Observation for Measurement of Environment Scales) Results G1 higher post-intervention scores than G2 (no significance testing reported) Measure 2 Competence pre vs. post intervention Results Negative affect (below median on Brief Symptom Inventory) G1: 3.1 (SD 0.9) → 3.4 (0.6) G2: 2.9 (0.9) → 3.6 (0.7) Non-negative G1: 3.1 (0.6) → 3.6 (0.6) G2: 3.1 (0.9) → 3.5 (0.6) Measure 3 Growth (wt for age, wt for ht, ht for age) (validated with Natl Center for Health Statistics charts) Results Significant improvement in each, no difference in improvement btw groups Measure 4 Parent-child behavior during feeding (validated: modified Parent Child Early Relational Assessment) Results No significant differences between groups | Health Outcomes: Measure 1 Cognitive and motor development (validated: Bayley Scales of Infant Development @ post- intervention; Battelle Developmental Inventory @ 4 y/o) Results Younger (1–12 mo at recruitment): G1: less decline pre/post vs. G2 (P = 0.02) Older (12.1–24.9 mo at recruitment): no significant difference in decline between groups Negative affect - cognitive G1: 96.6 (SD 17.0) → 86.2 (15.8) → 77.4 (18.3) G2: 91.8 (13.0) Measure 2 Language development (validated: Bayley Scales and Receptive/Expressive Emergent Language Scale) Results Receptive-younger G1: 92.7→88.5 G2: 98.7→88.0 Older G1: 92.3→83.2 G2: 98.3→82.7 (overall P = 0.05) Expressive - no differences in declines reported between groups Healthcare Utilization: NR | Costs (Economics): NR Measure 1 Annual per-child cost of home visits (ingredients method) Results $2,828/child/year Explanation of Overall Outcomes CHW home visit + multidisciplinary clinic management were significantly better than MDC alone in attenuating cognitive and motor decline among infants (but not older children) and attenuating receptive language decline; no significant difference observed in growth, expressive language, or parent-child interaction Quality Rating Fair Health Outcomes: Measure 1 Negative affect @ baseline, post- intervention, 4 y/o Results Negative affect group G1: 4.2 (SD 1.0) → 4.4 (0.7) → 3.5 (0.5) G2: 4.3 (0.7) → 4.4 (0.6) → 3.6 (0.3) Non-negative group G1: 4.2 (0.7) → 4.3 (0.6) → 3.7 (0.2) G2: 4.5 (0.5) → 4.4 (0.7) → 3.4 (0.6) Measure 2 Warmth @ 4 y/o Results Negative affect group G1: 2.8 (SD 0.5) G2: 2.9 (0.5) Non-negative group G1: 2.9 (0.5) G2: 2.5 (0.5)
Author Year Bone et al., 1989 Trial Name NA Objective or Aim Determine (1) feasibility and impact of introducing indigenious CHWs into ED to supplement detection, referral, and follow-up efforts performed by ED clinical staff (2) degree to which CHWs efforts improve HBP follow-up in high- risk groups Geography Baltimore, MD Organization Johns Hopkins Hospital Adult ER Type of Community Predominately black, low-income Study Design Prospective cohort Start Date 1982 Duration 2 years | Eligible (N) 722 Enrolled (N) 722 Randomized (N) NA Completers (N) NA Withdrawals or Dropouts (N) NA Health Condition of Interest HTN Inclusion Criteria ER patients scheduled for BP follow- up Exclusion Criteria Patients without a telephone number Groups G1: control (not able to be contacted by CHW) G2: contacted by CHW Initially, all patients were contacted initially by CHWs in ER. CHWs took pulse and BP measurements, provided educational counseling, identiifed barriers related to referrals, assisted Interventions G1: none G2: telephone preappointment reminder for scheduled BP follow- up, including education counseling. Multple attempts (at least 3) were made to contact patients 1–2 days before scheduled follow-up. Telephone encounters lasted 5–10 minutes, conducted at night. Group (N) G1: 278 G2: 444 | Title of CHW CHW Paid or Volunteer NR Relationship with Community Individuals residing in community where ED is located and interested in HBP (usually b/c of family or personal history). All women, age 30–45 years. CHW (N) 6 Supervision of CHW Initially by community health nurse/health educator on adaily basis, later reduced to weekly as HCWs were judged competent by nurse educator and ED staff Prior Training No prior work in health related area but some had previous community service; all had HS education Type of Service Face-to-face session; Telephone Type of Educational Materials Used Verbal Duration of Interaction with Clients 1 face-to-face session (≈20 minutes) and at least 1 pre- followup appointment reminder telephone call (5–10 minutes) (time period over which this occurred NR) Length of Follow-up NR | Age (mean) NR Sex (% female) NR Race (%) NR Other Role of CHW in Recruiting and Retention CHW was to contact patients for pre-appointment reminders Recruitment Rates NA Retention Rates NA | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: NR Healthcare Utilization: Measure 1 Returned to ED for follow-up appt Results G1: 41% G2: 60% (P < 0.001) | Costs (Economics): NR Explanation of Overall Outcomes NR Quality Rating Poor
Author Year Campbell, 2004 Trial Name WATCH Objective or Aim Compare effectiveness of 2 strategies to promote colorectal cancer preventive behaviors among African American members of 12 rural North Carolina churches. Geography Rural NC Organization Churches in rural counties Type of Community African American rural churches Study Design RCT Start Date 1999 Duration 1 yr | Eligible (N) 26 churches Enrolled (N) 12 churches Randomized (N) 12 churches Completers (N) NR (presumably 12 churches; completers/dropouts of individual participants from each church not reported) Withdrawals or Dropouts (N) NR (presumably 12 churches; completers/dropouts of individual participants from each church not reported) Health Condition of Interest Colorectal cancer Inclusion Criteria • Church in one of five rural eastern NC counties with at least 80 active members and expressed interest in participation • All active members (i.e., attending study church at least once/month) aged 18 or older were eligible to participate Exclusion Criteria NR Groups G1: Control G2: LHA only G3: TPV only G4: Combined LHA and TPV Interventions G1: Control churches offered health education sessions and speakers on topics of their choice not directly related to study objectives G2: Organize and conduct at least 3 church-wide activities on spreading info and enhancing support for healthy lifestyle and CRC screening (LHA) G3: 4 personalized computer- tailored newsletters and 4 targeted videotapes (TPV) corresponding to same behaviors mailed to participants' homes bimonthly for first 6 months after baseline data collection; 4th mailing was 9 months post baseline G4: LHA + TPV Group (N) G1: 129 G2: 123 G3: 159 G4: 176 | Title of CHW Lay health advisor Paid or Volunteer Volunteer Relationship with Community Church membership CHW (N) 62 Supervision of CHW NR Prior Training NR Type of Service Provide information through existing networks; organize and conduct at least three church-wide activities focused on spreading information for colorectal cancer prevention Type of Educational Materials Used TPV and combined groups (G2 and G4): videos, computer-tailored newsletters Duration of Interaction with Clients Three church- based activities during 12 months (time per session NR) Length of Follow-up 12 months | Age (mean) 52 Sex (% female) 74 Race (%) African American: 99% Other BMI ≥30: 40% Role of CHW in Recruiting and Retention Organize church activities, but recruitment is really NA in this case Recruitment Rates NR Retention Rates Participated in WATCH church activities (%): G1: 22.5 G2: 32.5 G3: 23.3 G4: 16.5 | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: Measure 1 Dietary change--daily fruit and vegetable servings (Baseline/Followup) Results G1: 3.3/3.4 G2: 3.5/3.5 G3: 3.3/3.9 G4: 3.4/3.7 P = 0.02 for G3 vs. G1 P = ns for G2 vs. G1 Measure 2 Physical Activity: recreational (moderate-vigorous) activity MET hours/week, M (SE) (baseline/followup) Results G1: 9.3 (0.88)/8.4 (0.69) G2: 10.5 (0.90)/10.6 (0.70) G3: 9.5 (0.80)/10.9 (0.61) G4: 9.7 (0.76)/9.7 (0.60) P = 0.07 for G2 Healthcare Utilization: Measure 1 Other CRC test in past year (% Baseline/% Followup) Results G1: 20.3/27.5 G2: 19.6/25.5 G3: 23.7/21.1 G4: 26.4/14.9 P = ns Measure 2 FOBT test in past year (% Baseline/% Followup) Results G1: 30.4/21.7 G2: 23.5/33.3 G3: 19.7/36.8 G4: 19.5/31.0 P = 0.08 | Costs (Economics): NR Explanation of Overall Outcomes NR Quality Rating Poor Health Outcomes: NR
Author Year Caulfield et al., 1998 Trial Name NR Objective or Aim To promote breast feeding among African-American women Geography Baltimore, MD Organization Organizational - WIC Type of Community Neighborhood- socioeconomic Study Design RCT Start Date 1992 Duration Various - from minimal to 20 weeks | Eligible (N) 4 clinics, 674 women Enrolled (N) 548 Randomized (N) 4 clinics Completers (N) 242 Withdrawals or Dropouts (N) 306 Health Condition of Interest Breast feeding Inclusion Criteria African-american woman attending prenatal care at participating clinic before 24 weeks gestation, singleton, planning to keep baby and remain in catchment area Exclusion Criteria Contraindications to BF; HIV, certain meds, pregnancy termination, twins, miscarriage, still birth, maternal or neonatal hospitalizatiion for 2 or more weeks Groups G1: Control G2: Video G3: Peer counselor G4: Video and Peer Counselor Interventions G1: All on-going WIC services as required by state and federal regulation G2: WIC services plus motivational video additional literature G3: WIC services plus peer counselling before and after birth G4: WIC services plus video plus peer counselling Group (N) G1: 57 G2: 64 G3: 55 G4: 66 | Title of CHW Peer counselor Paid or Volunteer NR Relationship with Community Shared condition - WIC recipient that successfully breast fed in past CHW (N) NR Supervision of CHW Random quality assurance visit to one clinic each week Prior Training 5 weeks of training Type of Service One-on-one counselling Type of Educational Materials Used Various - NR Duration of Interaction with Clients 3 or more meetings during pregnancy (from 24 weeks of gestation) and then weekly up to 16 weeks postpartum if they continued breast feeding Length of Follow-up Up to 16 weeks post partum | Age (mean) G1: < 18 37%, 18–25 40%, > 25 23% G2: < 18 27%, 18–25 53%, > 25 20% G3: < 18 33%, 18–25 40%, > 25 27% G4: < 18 23%, 18–25 53%, > 25 24% Sex (% female) 100 Race (%) 100% African- American Other Nulliparity G1: 23% G2: 48% G3: 20% G4: 32% < HS G1: 86% G2: 64% G3: 75% G4: 85% Employed G1: 13% G2: 33% G3: 17% G4: 28% Role of CHW in Recruiting and Retention: NR Recruitment Rates: NR Retention Rates: NR | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: Measure 1 Still breast feeding at 7–10 days Results G1: 14% OR 1.00 G2: 30% OR 0.79 95% CI, (0.25, 2.52) G3: 38% OR 1.11 95% CI, (0.34, 3.61) G4: 38% OR 1.52 95% CI, (0.50, 4.59) P < 0.05 Measure 2 Odds of intitiating and continuing BF (@7–10 d) relative to control group Results G1: 1 (control) G2: 1.36 (0.52, 3.54)/0.79 (0.25, 2.52) G3: 3.84 (1.44, 10.21)/1.11 (0.34, 3.61) G4: 1.92 (0.78, 4.76)/1.52 (0.50, 4.59) Measure 3 Intiation of breast feeding Results G1: 26% (OR, 1.00) G2: 50% (OR, 1.36; 95% CI, 0.52–3.54) G3: 62% (OR, 3.84; 95% CI, 1.44–10.21)G4: 52% (OR, 1.92; 95% CI, 0.78–4.76) Healthcare Utilization: NR | Costs (Economics): NR Explanation of Overall Outcomes CHW were effective at increasing initiation of BF, but no difference in continuation at 7–10 days Quality Rating Poor
Author Year Conway et al., 2004 Trial Name NR Objective or Aim Evaluate a culturally tailored behavioral problem solving intervention to reduce environmental tobacco smoke exposure amongst young Latino children Geography San Diego County Organization Areas with large Latino population Type of Community Community organizations and venues Study Design RCT Start Date NR Duration 12 months | Eligible (N) NR Enrolled (N) 143 Randomized (N) 143 Completers (N) 127 Withdrawals or Dropouts (N) 16 Health Condition of Interest Environmental tobacco smoke exposure Inclusion Criteria • Latino • Have child 1-9 y/o • Exposure of child to 6+ cigarettes/week Exclusion Criteria NR Groups G1: CHW G2: control Interventions G1: Home and telephone visits on problem-solving techniques to reduce environmental tobacco smoke exposure; 6 visits over 4 months G2: Participated in surveys but received no other intervention Group (N) 1 adult + 1 child dyad G1: 71 G2: 72 | Title of CHW Promotora Paid or Volunteer NR (text implies volunteer) Relationship with Community Bicultural, bilingual, Latina CHW (N) NR Supervision of CHW NR Prior Training NR Type of Service Home and telephone visits on problem-solving techniques to reduce ETS exposure to children Type of Educational Materials Used Contracting, shaping, positive reinforcement, problem solving, social support Duration of Interaction with Clients 6 home and telephone visits over 4 months (time per session NR) Length of Follow-up 12 mo | Age (mean) 33 y (adults), 4 y (children) Sex (% female) • Adult: Nearly 100% • Children: 55% Race (%) 100% Latino Other • Income: $700-1099/mo • Mexican-born: 85% • Acculturation: 2.0/5 • Mexican-educated: 71% • Median education: 9-11 y Role of CHW in Recruiting and Retention NR Recruitment Rates NR Retention Rates 81% overall | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: Measure 1 RIA of child's hair for nicotine and cotinine Results No significant differences between groups Measure 2 Parent report of child's past month ETS exposure Results No significant differences between groups Healthcare Utilization: NR | Costs (Economics): Measure 1 CHW intervention cost (estimated) Results $29000 Explanation of Overall Outcomes No difference observed in subjective or objective measures of ETS exposure with CHW visits vs. control Quality Rating Fair
Author Year Corkery et al., 1997 Trial Name NR Objective or Aim Determine effect of bicultural CHW on completion of diabetes education in inner-city Hispanic patient population and evaluate impact of completion of education program on patient knowledge, self- care behaviors, and glycemic control. Geography NYC - East Harlem Organization Cultural: Hispanic- Americans, primarily PR origin, and African- Americans Type of Community Disease: diabetes, neighborhood, socio-economic, cultural Study Design RCT Start Date NR Duration Mean 3.4 months (range 0.9 to 5.4) | Eligible (N) 64 Enrolled (N) 64 Randomized (N) 64 Completers (N) 40 (63%) Withdrawals or Dropouts (N) 24 (37%) Health Condition of Interest Diabetes Inclusion Criteria • Newly referred to clinic for patient education • Hispanic • > 20 yrs old Exclusion Criteria None Groups G1: Intervention G2: Control Interventions G1: Intervention- CHW acted as liason, attended clinic sessions, interpreter, reinforced self are instructions and appointment reminders G2: Control - encounters occurred between nurse and patient only Group (N) G1: 30 G2: 34 | Title of CHW CHW Paid or Volunteer NR Relationship with Community Bicultural, bilingual Hispanic-American of Puerto Rican heritage who lived in East Harlem CHW (N) 1 Supervision of CHW NR Prior Training Previously volunteered in a diabetes clinic Type of Service Attended clinic visits Type of Educational Materials Used NR Duration of Interaction with Clients Varied (mean = 3.4 months, range: 0.9-5.4), time per session equal to clinic visit duration Length of Follow-up Mean - 7.7 months (range 6-16.2) | Age (mean) 52.8 years Sex (% female) 74 Race (%) 100% Hispanic Other 46% literate Role of CHW in Recruiting and Retention NR Recruitment Rates NR Retention Rates NR | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: Measure 1 HgbA1c Results No difference in mean change between groups Measure 2 Diabetes Education Program Completion Results G1: 80% G2: 47% (P = 0.01) Healthcare Utilization: NR | Costs (Economics): NR Explanation of Overall Outcomes NR Quality Rating Fair
Author Year Derose et al., 2000; Dean et al., 2000; Derose et al., 2000; Stockdale et al., 2000; Fox et al., 1998 Trial Name Los Angeles Mammography Promotion Objective or Aim Assess effectiveness of telephone counseling in a church-based mammography promotion intervention trial Geography LA county Organization Telephone counseling Type of Community Church communities Study Design RCT Start Date 1996 Duration 2 years | Eligible (N) 1,969 on first screening 1,777 on second screening Enrolled (N) 1443 Randomized (N) 1113 Completers (N) 813 Withdrawals or Dropouts (N) 300 Health Condition of Interest Breast cancer screening Inclusion Criteria Women ages 50–80, living in private residencies, not being too ill or impaired to be interviewed, being able to be interveiwed in English or Spanish, living in a sample area, and being reachable by telephone Exclusion Criteria NR Groups G1: Control G2: CHW Interventions G1: Control churches provided minimal intervention: a library of resource materials on cancer and cancer prevention, assistance with starting a health committee or working with an existing health committee, computer hardware, software, and a printer, as well as computer training for at least one church member G2: One session of telephone counseling annually, for 2 years, by peer counselor; counseling individualized to address barriers, churches also received computer support offered to control churches Group (N) G1: 397 G2: 416 | Title of CHW Peer counselor Paid or Volunteer Some full-time staff, telephone counselors paid $150 stipend per year Relationship with Community Hired from participating churches assigned to telephone counseling CHW (N) 26 Supervision of CHW NR Prior Training NA Type of Service Barrier-specific telephone counseling to promote screening, discussion of resources for free- and reduced-cost mammograms, translation services, transportation, and childcare assistance Type of Educational Materials Used Verbal Duration of Interaction with Clients 2 telephone calls (one per year over 2 years), time per session 7-11 minutes on average Length of Follow-up 2 years | Age (mean) NR Sex (% female) 100 Race (%) NR Other Role of CHW in Recruiting and Retention NA Recruitment Rates NA Retention Rates NA | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: NR Healthcare Utilization: Measure 1 Nonadherence to mammogram, by self-report Results Nonadherence rates among adherent users at baseline: G1: 23.3% G2: 15.8% (P = 0 .029) Nonadherence rate among nonadherent users at baseline G1: 37.4% G2: 34.8 (P = 0.324) | Costs (Economics): Measure 1 Sensitivity Analysis Results Assuming that all labor is voluntary and that churches provide materials and resources: • Cost per additional screening for a LAMP study participant = $188; • Cost if all participants are adherent at baseline = $145; • Cost if all participants nonadherent at baseline = $419 (using LAMP effectiveness rates for adherent (7.5%) and nonadherent (2.6%) participants Explanation of Overall Outcomes NR Quality Rating Fair
Author Year Dignan et al., 2005 Trial Name Objective or Aim Determine relative effectiveness of face-to-face and telephone delivery of culturally sensitive Navigator intervention to increase adherence to guidelines for mammography screening among American Indian women Geography Denver metropolitan area Organization Urban American Indian Women Type of Community NR Study Design RCT Start Date August 2001 Duration One year | Eligible (N) 929 Enrolled (N) 157 (for intervention groups, N for control NR) Randomized (N) 157 (for intervention groups, N for control NR) Completers (N) 157 (for intervention groups, N for control NR) Withdrawals or Dropouts (N) 157 (for intervention groups, N for control NR) Health Condition of Interest Breast cancer screening Inclusion Criteria Urban American Indian women 40 years and older living in greater Denver Metropolitan area and had not had a mammogram within previous 18 months Exclusion Criteria Groups G1: control G2: face-to-face G3: telephone intervention Interventions G1: Control, interventions not reported, data from Colorado Mammography Program data G2: Tailored education brochure using data from baseline interview. face-to-face planned for delivery at participant's home (1 session lasting 20-90 minutes), presenting information on breast cancer and value of early detection, review of brochure G3: Telephone intervention, as above Group (N) G1: G2: 77 G3:133 | Title of CHW Native sister/Navigators Paid or Volunteer NR Relationship with Community Recruited from Denver metro area CHW (N) N Supervision of CHW NR Prior Training NR Type of Service Barrier-specific counseling to promote screening, face- to-face vs. telephone Type of Educational Materials Used Tailored educational brochure Duration of Interaction with Clients One time session 20–90 minutes Length of Follow-up 6 months | Age (mean) 54.2 years Sex (% female) 100 Race (%) Native Americans Other Role of CHW in Recruiting and Retention NR Recruitment Rates NR Retention Rates NR | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: NR Healthcare Utilization: Measure 1 Mammograms over past 12 months (self-report) Results G1: 51.9 -- > 50.0 G2: 29 -- > 41.8 G3: 34.4 -- > 45.2 Chi-square G1 vs G2+G3:2.68, P = 0.10; P for G2 vs G3: 0.83; P for G2, pre-post changes: 0.029; P for G3, pre-post changes: 0.197 | Costs (Economics): NR Explanation of Overall Outcomes NR Quality Rating Poor
Author Year Duggan et al., 1999; Duggan et al., 2000 Trial Name Hawaii’s Healthy Start Program (HSP) Objective or Aim Prevent child abuse and neglect and promote child health and development in newborns of families at risk for poor child outcomes Geography Hawaii Oahu Organization Organizational Type of Community At risk for chid abuse Study Design RCT Start Date 1994 Duration 2 years | Eligible (N) 901 families Enrolled (N) 730 families Randomized (N) 730 families Completers (N) 566 at 2 years Withdrawals or Dropouts (N) 164 families Health Condition of Interest Child abuse Inclusion Criteria Lived in target community, and not known to child protective services Exclusion Criteria Non-English speaking Groups G1: Healthy Start Program G2: Control G3: Test Control Interventions G1: Home visiting with individualized service plans, child developmental screenings, and mother-child interaction assessments; family support plan within 45 days of initial visit, reviewed q 6 mo, revised annually; periodic screening for DD, observational assessment of parent-child interaction and home environment; ensure existence of medical home, links to other needed resources G2: Control G3: Test Control was only interviewed at end Group (N) G1: HSP: 373 G2: Control: 270 G3: Test Control: 41 | Title of CHW Home visitors Paid or Volunteer NR Relationship with Community from community CHW (N) NR Supervision of CHW Non-clinician- met weekly w/home visitors Prior Training NR Type of Service Counselling--building relationship with families; active assistance to address existing crises; model problem-solving skills and effective parent-child interaction; link families with needed resources; provide parenting education; ensuring presence of medical home for children Type of Educational Materials Used NR Duration of Interaction with Clients ≈ 22 visits (1 hour each) over 2 years [Protocol called for weekly visits] Length of Follow-up 2 years | Age (mean) Mother's average age G1: 24 years G2: 24 years Sex (% female) 100 Race (%) G1: Hawaiian: 21% Pacific Islander: 13% Asian: 10% Filipino: 18% Caucasian: 11% Multiracial or unknown: 28% G2: Hawaiian: 19% Pacific Islander: 14% Asian: 7% Filipino: 20 Caucasian: 13% Multiracial or unknown: 26% Other Role of CHW in Recruiting and Retention NA Recruitment Rates NA Retention Rates NA | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: Measure 1 Bayley Scales of Infant Development, Mental Development Index at 2 years post-intervention Results G1: 90.0 G2: 89.2 P = 0.60 Measure 2 Bayley Scales of Infant Development, Psychomotor Development Index at 2 years post-interventino Results G1: 92.1 G2: 90.4 P = 0.12 Measure 3 Has primary care provider? Results G1: 91% G2: 86% P = 0.09 Healthcare Utilization: Measure 1 Adequate # of well-child visits Results G1: 89% G2: 84% P = 0.09 Measure 2 Immunizations up to date Results G1: 87% G2: 85% P = 0.45 | Costs (Economics): NR Explanation of Overall Outcomes NR Quality Rating Poor
Author Year Earp et al., 2002 Trial Name North Carolina Breast Cancer Screening Program Objective or Aim Determine effectiveness of lay health advisor intervention, supplemented by limited number of other activities, aimed at increasing self-reported mammography use among African American women 50 years and older in eastern North Carolina; correcting beliefs about causes of breast cancer; increasing acceptance of need for regular mammography Geography Eastern NC Organization Black women Type of Community Mostly rural, 37% minority, 12% below FPL; low likelihood of having had mammogram Study Design Prospective cohort for main analysis Start Date 1993 Duration 4 years | Eligible (N) 10 counties, 2441 women Enrolled (N) 2296 Randomized (N) 993 (African American) Completers (N) 801 Withdrawals or Dropouts (N) 192 Health Condition of Interest Breast cancer screening Inclusion Criteria • Living in study county • African-American • At least 50 y/o • no h/o breast cancer Exclusion Criteria • Death • Departure from study area • Admission to nursing home • Development of breast cancer • Prior participation in CHW training Groups G1: Counties receiving CHW and other targeted activity G2: Comparison Interventions G1: Counties receiving CHW and other targeted activity: presentations to community groups and events, one-on-one conversations, use of informational/motivational materials G2: Comparison counties, no intervention reported Group (N) G1: 390 G2: 411 | Title of CHW Lay health advisor Paid or Volunteer Volunteer Relationship with Community Members of community; same county CHW (N) 170 Supervision of CHW Main analysis: - described in Earp JA, Viadro CI, Vincus AA, et al. Lay health advisors: a strategy for getting word out about breast cancer. Health Educ Behav. 1997;24:432–451. 412 - by “community outreach specialists” monthly (meetings and assistance Prior Training NR Type of Service Presentations to community groups and events, one-on- one conversations, use of informational/motivational materials Type of Educational Materials Used Brochures, posters, church fans, holiday cards Duration of Interaction with Clients 2 community activities per month; one-on-one conversations once a week over a 24- month period, time per session NR Length of Follow-up 32 months | Age (mean) G1: 46% < 65, 23% > 74 G2: 44% < 65, 24% > 74 Sex (% female) 100 Race (%) African American 100% Other Income < $12k G1: 81% G2: 63%; No medical visits in past year G1: 9% G2: 7%; Low breast cancer knowledge G1: 43% G2: 31%; Low perceived support for breast cancer screening G1: 43% G2: 35% Role of CHW in Recruiting and Retention NR Recruitment Rates Main analyis: 87% all races (no recruitment rate given for African Americans or for G1/G2 412 - NR Retention Rates G1: 89% G2: 88% | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: Measure 1 Pre/post percentage point difference in reported mammogram, adjusted for change in mammography attitude Results • No recent mammogram at baseline: CHW advice: +9 diffused discussion: +10 project awareness: +15 • Recent mammogram at baseline: CHW advice: +8 diffused discussion: 0 project awareness: +5 Healthcare Utilization: Measure 1 Self-report of mammogram in past 2 years, stratified by income Results < $12k annually G1: pre 37%, post 59% G2: pre 49%, post 60% (adjusted P = 0.02); $12k or greater annually G1: pre 56%, post 59% G2: pre 73%, post 82% (adjusted P = 0.92) Measure 2 Self-report of mammogram in past 2 years Results G1: pre 41%, post 58% G2: pre 56%, post 67% (adjusted P = 0.05) | Costs (Economics): NR Explanation of Overall Outcomes CHW community intervention is associated with significantly higher proportions of African- American women reporting having received mammograms, especially among lower income strata Quality Rating Poor Health Outcomes: NR
Author Year Elder et al., 2006; Elder et al., 2005 Trial Name Secretos de la Buena Vida Objective or Aim Determine whether CHW + tailored print materials vs. tailored print materials vs. off- the-shelf print materials was more effective to maintain diet change at 1 y f/u Geography San Diego County Organization Spanish-dominant Latina Type of Community Central and southern regions Study Design RCT Start Date 2001 Duration 2 years | Eligible (N) 510 Enrolled (N) 357 Randomized (N) 357 Completers (N) 281 Withdrawals or Dropouts (N) 76 Health Condition of Interest Dietary behavior Inclusion Criteria • Female • 18–65 y/o • Hispanic surname • Spanish-dominant • Valid telephone number Exclusion Criteria • Pregnant • Medically prescribed diet • Not remaining in San Diego Groups G1: CHW + tailored print G2: tailored print G3: control Interventions G1: CHW home visits and/or phone calls + tailored print materials G2: 12 weekly tailored newsletters and homework G3: 12 weekly off-the-shelf dietary printed material Group (N) G1: 120 G2: 118 G3: 119 | Title of CHW Promotora Paid or Volunteer NR Relationship with Community Indigenous to community, Spanish language dominant, perceived as a community role model CHW (N) 4 Supervision of CHW NR Prior Training NR Type of Service G1: weekly home visits or telephone calls + tailored health info newsletters G2: tailored health info newsletters G3: population-targeted print materials Type of Educational Materials Used G1: negotiated behavioral change goals G1 and G2: tailored newsletters and activity inserts based on baseline participant data; magnets w/healthy lifestyle messages; recipes G3: language-appropriate materials w/dietary information developed for Latino popul Duration of Interaction with Clients 12 home visits or telephone calls over a 12-week period, 12 weekly tailored newsletters (duration per session NR) Length of Follow-up 1 year | Age (mean) G1: 38.6 (SD 10.1) G2: 40.4 (9.9) G3: 40.1 (9.8) Sex (% female) 100 Race (%) Hispanic Other Married G1: 94% G2: 93% G3: 93%; BMI G1: 28.9 (SD 5.7) G2: 30.4 (5.6) G3: > 29.6 (5.4) Role of CHW in Recruiting and Retention NR Recruitment Rates NR Retention Rates G1: 93/120 = 78% G2: 90/118 = 76% G3: 98/119 = 82% | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: Measure 1 % calories from fat (Nutrition Data System 24-h dietary recall interview) Results No significant difference between groups at 6 and 12 months post-intervention Measure 2 Total gm fiber (Nutrition Data System 24-h dietary recall interview) Results No significant difference between groups at 6 and 12 months post-intervention Measure 3 Total fat gm (Nutrition Data System 24-h dietary recall interview) Results No significant difference between groups at 6 and 12 months post-intervention Measure 4 Post-intervention calorie/fat intake (using Nutrition Data System) Results kcal (P < .01) G1: 1,286.9 G2: 1,419.2 G3: 1,436.2 (G1–G3 P < .05 G1–G2 P < .1) Fat gm (P < .05) G1: 43.1 G2: 49.8 G3: 49.3 (G1–G3 p < .1 G1–G2 P < .05) % fat cal G1: 29.3 G2: 30.4 G3: 30 (NS) Saturated fat gm (P < .05) G1: 14.4 G2: 16.9 G3: 16.6 (G1–G3 P < .1 G1–G2 Healthcare Utilization: NR | Measure 1 Cost per unit of change Results Per reduced fat gm G1: $8.28 G2: $5.11 G3: $1.30 Per reduced saturated fat gm G1: $21.09 G2: $17.31 G3: $3.21 Per reduced calorie G1: $0.36 G2: $3.21 G3: $0.07 Measure 2 Per-participant cost Results G1: $135 G2: $45 G3: 9 Explanation of Overall Outcomes NR Quality Rating Poor Measure 2 Dietary fiber intake (gm) (using Nutrition Data System) Results Total fiber gm G1: 16.1 G2: 17.2 G3: 15.6 (NS) Soluble fiber gm G1: 4.7 G2: 5.1 G3: 4.8 (NS) Insoluble fiber gm G1: 11.1 G2: 11.8 G3: 10.5 (NS) Measure 3 Other dietary intake (via NDS) Results CHO gm (P < .05) G1: 171.2 G2: 187.3 G3: 187.1 (G1–G3 P < .05 G1–G2 P < .1) Glucose gm ( P < .01) G1: 16 G2: 21.1 G3: 18.4 (G1–G3 NS) G1–G2 P < .05) Fructose gm ( P < .001) G1: 16.9 G2: 22.7 G3: 19.1 G1–G3 NS G1–G2 P < .05 G2–G3 P < .1) Sucrose gm G1: 30.5 G2: 31.2 G3
Author Year Erwin et al., 1997 Trial Name Witness project Objective or Aim Examine effectiveness of Witness Project, a culturally competent cancer education program that trains cancer survivors to promote early detection and increased breast self-examination and mammography in population of rural, underserved, African American women Geography Rural Mississippi River Delta region of Arkansas Organization Church or community group Type of Community Neighborhood Study Design Prospective cohort Start Date 1994 Duration 6 months | Eligible (N) NA Enrolled (N) 433 Randomized (N) NA Completers (N) 412 Withdrawals or Dropouts (N) 21 Health Condition of Interest BSE and mammography Inclusion Criteria Inclusion criteria for women NR, churches selected from convenience sample Exclusion Criteria NA Groups G1: Intervention G2: Control Interventions G1: Members of a Witness Project team, composed of 7 local African American women who had survived breast or cervical cancer, speak in groups of 2 to 5 at local churches and community organization meetings G2: Control group offered delayed intervention Group (N) G1: 204 (152 aged ≥ 40) G2: 206 (140 aged ≥ 40) | Title of CHW Witness role model Paid or Volunteer NR Relationship with Community Shared race, cancer survivors CHW (N) 7 Supervision of CHW NR Prior Training NR Type of Service Motivational speeches based on cancer survivor, experience of CHWs, breast self-exam lessons using a breast model, discussion of resources for free- and reduced-cost mammograms Type of Educational Materials Used NR Duration of Interaction with Clients One presentation, time NR Length of Follow-up 6 months | Age (mean) G1: 52.5 G2: 49.3 Sex (% female) 100 Race (%) 100% African-American Other Role of CHW in Recruiting and Retention NA Recruitment Rates NA Retention Rates NA | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: Measure 1 Breast self exam in past month (self-report) Results G1: 49% to 65.4% (P < 0.001 compared to baseline) G2: 65% to 72% (P = NS compared to baseline) Measure 2 Regular practice of breast self-exam (self-report) Results Baseline G1: 69.8% to 82% (P = NS compared to baseline) G2: 82% to 82% (P < 0.005 compared to baseline) Measure 3 Ever had mammography (self-report) Results G1: 52.4% to 64.4% (P < 0.05 compared to baseline) G2: 60.4% to 63.3% (P = NS compared to baseline) Healthcare Utilization: NR | Costs (Economics): NR Explanation of Overall Outcomes Through use of community churches and cancer survivors, breast cancer screening activities can be improved in this population Quality Rating Fair
Author Year Forst et al., 2004 Trial Name NR Objective or Aim Evaluate CHW model to reduce eye injuries and illnesses in Latino migrant and seasonal farm workers Geography SE Michigan, northern Illinois Organization Latino migrant and seasonal farm workers Type of Community Farm workers; high incidence of eye injury Study Design Prospective cohort Start Date 2001 Duration 16 wk | Eligible (N) 36 farms, total workers NR Enrolled (N) 34 farms, 1,000 workers Randomized (N) 786 Completers (N) 703 Withdrawals or Dropouts (N) 83 Health Condition of Interest Eye injury Inclusion Criteria Farm owners’ consent Exclusion Criteria NR Groups G1: CHW + protective eyewear + training + information sheet G2: CHW + eyewear + information sheet G3: Eyewear + information sheet Interventions G1: CHW worked w/subjects, trained subjects on eye health and safety (minimum of 2 training sessions = 1 individual + 1 group) G2: CHW distributed eyewear w/o additional training G3: Research team distributed eyewear w/o additional training Group (N) G1: 256 (141 IL, 115 MI) G2: 298 (179 IL, 119 MI) G3: 149 (78 IL, 71 MI) | Title of CHW Promotor de salud Paid or Volunteer NR Relationship with Community Actively employed farm workers; Spanish fluency CHW (N) 16 Supervision of CHW Weekly with promotor- coordinators from study team Prior Training Demonstrated leadership and communication skills; demonstrated respect for farm workers and owners Type of Service G1: CHW worked w/subjects, trained subjects on eye health and safety G2: CHW distributed eyewear w/o additional training Type of Educational Materials Used G1: Trainer training; reference manual on agricultural eye illness and injury; photos and fotonovelas; tool kit to demonstrate eye injuries and hazards Duration of Interaction with Clients G1: At least 1 individual and at least 1 group session during farming season (duration per session NR) Length of Follow-up 16 wk | Age (mean) G1: 33.5 G2: 32.4 G3: 32.8 Sex (% female) G1: 24 G2: 19 G3: 15 Race (%) 90% Mexican 10% Mexican-American Other • Read Spanish: 77% • < 8 y school: 75% • < 4 y school: 25% • Read English: 16% Role of CHW in Recruiting and Retention G1: Recruited and worked alongside subjects, collected data G2: Recruited, collected data Recruitment Rates 786/1000 = 78.6% Retention Rates G1: 67/186 = 36% G2: 172/198 = 87% G3: 76/107 = 71% | Knowledge, Attitude, and Behavior: Measure 1 Pre/post change in % wearing safety glasses Results Self-report: G1: 1.48 (P < .0001) G2: 0.71 (P < .0001) G3: 0.96 (P < .0001) G1–G2 P < .0001 G1–G3 P = .03 G1 and 2–G3 P = .0004 Observed: G1: 1.1→36% G2: 0→5.2% G3: 0→14%) Measure 2 Pre/post subject risk perception of eye injury Results Results not interpretable Quality of Life: NR | Health Outcomes: Measure 1 Cumulative number of eye injuries for season Results IL 11 cases pterygium; MI 4 (both likely underreported) Healthcare Utilization: NR | Costs (Economics): NR Explanation of Overall Outcomes CHW intervention increased reported and observed use of protective eyewear, more so with associated training Quality Rating Poor
Author Year Frate et al., 1985; Frate et al., 1983 Trial Name NR Objective or Aim Evaluation of different interventions to contol hypertension in a rural setting Geography Central Mississippi Organization Cultural Type of Community Hypertension and rural community Study Design Observational- quasi-experimental Start Date Early 1980's Duration 18 months | Eligible (N) NR Enrolled (N) NR Randomized (N) NA Completers (N) 667 Withdrawals or Dropouts (N) NR Health Condition of Interest Hypertension Inclusion Criteria Patients with physician confirmed hpertension Exclusion Criteria NA Groups G1: Hypertension Health Counselors G2: Family based self help G3: Church based self help Interventions Group (N) G1: 207 G2: 131 G3: 229 | Title of CHW Hypertension Health Counselors Paid or Volunteer Volunteer Relationship with Community Native CHW (N) 5 Supervision of CHW NR Prior Training Certified and equipped to measure blood pressure Type of Service Monitoring BP, education and support Type of Educational Materials Used NR Duration of Interaction with Clients Monthly visits over 18 months (time per session NR) Length of Follow-up 18 months | Age (mean) NR Sex (% female) NR Race (%) NR Other Role of CHW in Recruiting and Retention NR Recruitment Rates NR Retention Rates NR | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: Measure 1 Proportion controlled Results G1: 80.6% G2: 90.0% G3: 79.9% Healthcare Utilization: NR | Costs (Economics): NR Explanation of Overall Outcomes NR Quality Rating Extra Poor!
Author Year Gielen et al., 2002 Trial Name NA Objective or Aim Present results of an intervention trial to enhance parents' home- safety practices through pediatric safety counseling, home visits and an on-site children's safety center where paretns receive personalized education and can purchase reduced- cost products Geography NR (probably Baltimore, MD) Organization Pediatric resident continuity clinic in large, urban teaching hospital Type of Community Same Study Design RCT Start Date NR Duration 18 months | Eligible (N) 43 first- and second-year residents; 305 patients' parents Enrolled (N) 39 residents; 187 families Randomized (N) 39 residents; 187 families Completers (N) 122 families Withdrawals or Dropouts (N) 11 became ineligible, 15 refused further contact, 39 unable to contact Health Condition of Interest Pediatric safety Inclusion Criteria •Residents: all first- and second- year residents • Parent-patient dyads of participating residents were then approached in clinic waiting room - elgibiliy criteria included infants 6 mos or younger, free of serious medical problems, caretakers were english-speaking and lived with child Exclusion Criteria See prior Groups G1: Standard intervention G2: Enhanced intervention Interventions Both groups of pediatric residents invited to attend 1-hour seminar on problme of injuries; both groups received 5-hr EAG training program G1: received safety counseling and referral to children's safety center from their pediatrician G2: received standard services plus "offer of" a home-safety visit from a CHW Group (N) G1: 20 residents, 93 parents G2: 19 residents, 94 parents | Title of CHW CHW Paid or Volunteer NR Relationship with Community NR CHW (N) NR Supervision of CHW NR Prior Training NR Type of Service Home visits between 6 and 9 mo well child checks: assessed injury hazards; made recommendations about appropriate safety products and practices; referred families to CSC Type of Educational Materials Used NR Duration of Interaction with Clients 1 home-safety visit sometime between patient’s 6- and 9-month well-infant visits (duration of session NR) Length of Follow-up NA | Age (mean) Mean age of mother = 24 years Sex (% female) Parents 98% female Race (%) 94% AA Other NR Role of CHW in Recruiting and Retention NA Recruitment Rates NA Retention Rates NA | Knowledge, Attitude, and Behavior: Measure 1 Poisons kept latched or locked Results G1: 12% G2: 10% P-value not reported Measure 2 Presence of ipecac Results G1: 27% G2: 31% P-value NR Quality of Life: Measure 1 Hot water ≤ 48.9 C Results G1: 47% G2: 47% P-value NR Measure 2 Working smoke alarm Results G1: 84% G2: 81% P-value NR Measure 3 Stairs protected by gate or door, Results G1: 23% G2: 27% P-value NR | Health Outcomes: NR Healthcare Utilization: NR | Costs (Economics): NR Explanation of Overall Outcomes NR Quality Rating Fair
Author Year Graham et al., 1992 Trial Name NR Objective or Aim Prevention of low birth weight using home intervention Geography Cleveland Organization Organizational clinic-derived sample Type of Community Inner city black Study Design RCT Start Date 1987 Duration NR | Eligible (N) 190 145 (190 total used to validate instrument, but some were ineligible at > 28 wk) Enrolled (N) 145 Randomized (N) 87 in experimental group, 145 overall Completers (N) 52 in experimental group 110 total Withdrawals or Dropouts (N) 35 out of 87 in experimental group Health Condition of Interest Low birth weight Inclusion Criteria • Black •Between 17th and 28th week of gestation • Low family functioning score • At least 1 stressful life event prior to registration • Registering at study clinic during specified period Exclusion Criteria • Living > 5 mi from clinic • Limited reading ability Groups G1: Experimental G2: Control Interventions G1: Experimental - 4 home visits G2: Control Group (N) G1: Experimental- 87 G2: Control - 58 | Title of CHW Home visitors Paid or Volunteer NR Relationship with Community Shared race and gender having children of their own CHW (N) 2 Supervision of CHW NR Prior Training motherhood Type of Service Home visits: psychosocial support to patient and encouragement to family to be supportive of pregnancy, accomplished through education about pregnancy and encouragement of significant others to attend home visits, clinic visits, clinic Type of Educational Materials Used NR Duration of Interaction with Clients 4 visits (1 hour each) at 2-4 week intervals for 2 to 5 months (until birth of child) Length of Follow-up Birth of child | Age (mean) 24 y Sex (% female) 100 Race (%) Black 100% Other • 38% primiparous • 11% married • 84% receiving Medicaid Role of CHW in Recruiting and Retention NR Recruitment Rates • 1326 screened • 190 high-risk • 145 randomized Retention Rates G1: 52/87 completed all 4 visits (60%) G2: 100% (only birth information needed for this group) | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: Measure 1 LBW rate Results G1: (All): 12.9% (P = 0.51) G1: (Completers): 7.7% (P = 0.98) G2: 7.5% Healthcare Utilization: Measure 1 Ratio of actual:expected prenatal clinic visits Results G1 (All): 1.12 (SD 0.48, P = 0.029) G1 (Completers): 1.17 (SD 0.46, P = 0.007) G2: 0.93 (SD 0.44) | Costs (Economics): NR Explanation of Overall Outcomes CHW home visits increased utilization of prenatal clinic care, but had no effect on LBW incidence Quality Rating Fair
Author Year Hiatt et al., 2008 Trial Name Breast and Cervical cancer Intervention Study (BACCIS) Objective or Aim Effect of Breast and Cervical Cancer Intervention Study (BACCIS), a multi- component conducted in San Francisco Bay Area between 1992 and 1997. Geography San Francisco, CA Organization Hospital Type of Community Income, Neighborhood Study Design Modified 2x2 design in 8 neighborhoods Start Date 1993 Duration 4 years | Eligible (N) 25,000 Enrolled (N) NA Randomized (N) NA Completers (N) 1,616 Withdrawals or Dropouts (N) NR Health Condition of Interest Cancer Inclusion Criteria Women living in area of interest Exclusion Criteria NR Groups G1: Intervention G2: Control Interventions G1 one-on-one visits at various events and locations; presentations to community-based organizations (agencies); and Women’s Health Days, offering free mammograms, Pap tests, and breast self- examination instruction. G2: Control Group (N) G1: 801 G2: 798 | Title of CHW Lay health workers Paid or Volunteer Paid Relationship with Community Locally recruited CHW (N) NR Supervision of CHW NR Prior Training Intensively trained in basic breast and cervical cancer biology, screening and treatment, and availability of health care and screening services Type of Service Support and information Type of Educational Materials Used NR Duration of Interaction with Clients Unspecified # of interactions (length per session NR) over 2 years Length of Follow-up 4 years | Age (mean) ~60% > 50 yrs Sex (% female) 100 Race (%) White: 31 Black: 30 Latina: 14% Latina Chinese: 17% Other: 7% Other NR Role of CHW in Recruiting and Retention NR Recruitment Rates NR Retention Rates NR | Knowledge, Attitude, and Behavior: Measure 1 Ever completed breast self- examination (Total N [%]pretest/Total N [%] posttest) Results G1: 800 (89)/810 (92) Χ^2^ = NR, P=0.031 G2: 793 (83)/ 802(81) Χ^2^ = NR, not significant Measure 2 Completed breast self- examination monthly in past year (Total N [%]pretest/Total N [%] posttest) Results G1: 800 (24)/808 (26) Χ^2^ = NR, not significant G2: 793 (18)/ 801(23) Χ^2^ = NR, P=0.018 Quality of Life: NR | Health Outcomes: NR Healthcare Utilization: Measure 1 Ever completed mammography (Total N [%]pretest/Total N [%] posttest) Results G1: 798 (83)/812 (86) Χ^2^ = NR, not significant G2: 798 (68)/ 803 (77) Χ^2^ = NR, P=0.001 Measure 2 Ever completed mammography (logistic regression, 95% CI) Results Residence in outreach area over time: 0.7 (0.5, 1.0) Measure 3 Completed mammography in the past 2 years (Total N [%] pretest/Total N [%] posttest) Results G1: 798 (73)/812 (71) Χ^2^ = NR, not significant G2: 798 (57)/ 803 (62) Χ^2^ = NR, P=0.022 Measure 4 Completed mammography in past 2 years (logistic regression, 95% CI) Results Residence in outreach area over time: 0.7 (0.5, 1.0) Measure 5 Completed 3 or more mammographies in past 5 years (Total N [%] pretest/Total N [%] posttest) Results G1: 794 (50)/812 (51) Χ^2^ = NR, not significant G2: 794 (35)/ 803 (41) Χ^2^ = NR, P=0.008 Measure 6 Completed 3 mammographies in past 5 years (logistic regression, 95% CI) Results Residence in outreach area over time: 0.8 (0.5, 1.1) Measure 7 Ever completed clinical breast examination (Total N [%]pretest/Total N [%] posttest) Results G1: 801 (94)/812 (95) Χ^2^ = NR, not significant G2: 798 (82)/ 803 (87) Χ^2^ = NR, P=0.006 Measure 8 Completed clinical breast examination in past year (Total N [%] pretest/Total N [%] posttest) Results G1: 800 (75)/809 (74) Χ^2^ = NR, not significant G2: 796 (56)/ 803 (60) Χ^2^ = NR, not significant Measure 9 Completed 3 or more clinical breast examinations in past 5 years (Total N [%] pretest/Total N [%] posttest) Results G1: 793 (73)/809 (73) Χ^2^ = NR, not significant G2: 792 (54)/ 800 (54) Χ^2^ = NR, not significant Measure 10 Ever completed pap smear (Total N [%] pretest/Total N [%] posttest) Results G1: 801 (95)/812 (96) Χ^2^ = NR, not significant G2: 798 (83)/ 801 (87) Χ^2^ = NR, P=0.021 Measure 11 Ever completed Pap smear (logistic regression, 95% CI) Results Residence in outreach area over time: 1.5 (0.6, 4.2) Measure 12 Completed pap smear in past 3 years (Total N [%]pretest/Total N [%] posttest) Results G1: 799 (84)/811 (87) Χ^2^ = NR, not significant G2: 798 (69)/ 801 (75) Χ^2^ = NR, P=0.009 Measure 13 Completed Pap smear in the past 3 years (logistic regression, 95% CI) Results Residence in outreach area over time: 0.9 (0.6, 1.3) | Costs (Economics): NR Explanation of Overall Outcomes NR Quality Rating Fair
Author Year Hunter et al., 2004 Trial Name NR Objective or Aim Test effectiveness of a CHW (promotora) program to increase compliance with annual preventive exams among uninsured Hispanic women, aged 40 and older, living at US-Mexico border Geography US-Mexico border communities: Douglas, Arizona - 16,500 residents Organization cultural/community Type of Community Latina women Study Design RCT Start Date 1999 Duration 1 year | Eligible (N) 151 Enrolled (N) 103 Randomized (N) 101 Completers (N) 98 Withdrawals or Dropouts (N) 3 Health Condition of Interest Preventive care - Women’s health Inclusion Criteria • Aged 40 or older • Residents of household • Not pregnant • At least 2 months postpartum • US women who participated in an initial comprehensive clinical exam Exclusion Criteria Groups G1: Postcard G2: Promotora Interventions G1: received postcards in mail 2 weeks before month their annual exams were due, printed in language used to complete original questionnaire G2: Received postcard reminders and were visited by promotora 2 weeks after postcard had been mailed. Promotora facilitated appointment scheduling, contacted them to facilitate rescheduling if appt was missed. Group (N) G1: 50 G2: 51 | Title of CHW Promotora Paid or Volunteer NR Relationship with Community NR CHW (N) NR Supervision of CHW NR Prior Training NR Type of Service Home visits; telephone calls to facilitate appt scheduling for annual preventive exams Type of Educational Materials Used None Duration of Interaction with Clients One initial home visit and one final follow-up visit 8 weeks after postcard mailing to begin intervention(time per session NR) Length of Follow-up NA | Age (mean) 50.3 years Sex (% female) 100 Race (%) 96% Hispanic Other • Born in Mexico: 86% • Blow federal poverty line: 76% • Less than hs education: 77% Role of CHW in Recruiting and Retention NA Recruitment Rates NA Retention Rates NA | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: NR Measure 3 Healthcare Utilization: Measure 1 Returned to clinic for a second comprehensive annual exam Results G1: 48% (n = 24) G2: 65% (n = 33) RR, 1.35, 95% CI, 0.95–1.92 | Costs (Economics): NR Explanation of Overall Outcomes NR Quality Rating Fair
Author Year Jandorf et al., 2005 Trial Name NR Objective or Aim To determine whether a patient navigator (PN) would enhance CRC screening participation beyond physician recommendation alone in a neighborhood healthcare setting. Geography East Harlem, NYC Organization Inner city primary care practice Type of Community NR Study Design RCT Start Date 2002 Duration 6 months | Eligible (N) 125 Enrolled (N) NR Randomized (N) 78 Completers (N) 78 Withdrawals or Dropouts (N) 0 Health Condition of Interest Colorectal cancer Inclusion Criteria Men and women ≥ 50 yrs of age Exclusion Criteria FOBT within past yr; FS or barium enema within past 3–5 yrs; colonoscopy within past 10 yrs Groups G1: Patient navigator G2: Usual care Interventions G1: Navigated G2: Not navigated Group (N) G1: 38 G2: 40 | Title of CHW Patient Navigator Paid or Volunteer Paid Relationship with Community Shared community & ethnic background CHW (N) 1 Supervision of CHW NR Prior Training NR Type of Service Assistance with completing screening process including written and telephone reminders, scheduling & assistance; education; support and advocacy Type of Educational Materials Used NR Duration of Interaction with Clients Telephone calls (unspecified #, unspecified length) over 6 month period Length of Follow-up 6 months | Age (mean) G1: 61.1 G2: 61.2 Sex (% female) G1: 76.3 G2: 72.5 Race (% Hispanic) G1: 78.9 G2: 85.0 Other G1: Income ≤ $10,000: 72.2% ≥ HS education: 13.2 Had family history of cancer: 36.8% G2: Income ≤ $10,000: 64.1 ≥ HS education:10.0 Had family history of cancer: 38.5% Role of CHW in Recruiting and Retention PN approached prospective participants Recruitment Rates NR Retention Rates NR | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: NR Healthcare Utilization: Measure 1 Completed FOBT after 3 months (% yes) Results G1: 42.1 G2: 25.0 P = 0.086 Measure 2 Had endoscopy appointment at 3 months (%) Results G1: 18.4 G2: 0 P = 0.005 Measure 3 Completed endoscopy at 3 months (%) Results G1: 15.8 G2: 5.0 P = 0.115 Measure 4 Completed endoscopy at 6 months (%) Results G1: 23.7 G2: 5.0 P = 0.019 | Costs (Economics): NR Explanation of Overall Outcomes NR Quality Rating Fair
Author Year Korfmacher et al., 1999; Olds et al., 2002; Olds et al., 2004; Trial Name Home Visitation 2000 Objective or Aim Examine differences between CHWs and nurses in using home visitation to reduce incidence of child maltreatment; to examine distal effects of prenatal and infancy home visiting by CHWs or nurses, at 2–4 y/o Geography Denver Organization Recruited from prenatal clinics Type of Community Low-income Study Design RCT Start Date 1994 Duration 15 mo | Eligible (N) 1178 Enrolled (N) 735 Randomized (N) 735 Completers (N) 560 Withdrawals or Dropouts (N) 175 (n at 24 month assessment), 130 (n at 4 year assessment) Health Condition of Interest Child maltreatment; maternal and child health Inclusion Criteria Pregnant; Medicaid-qualified or no private insurance Exclusion Criteria Previous live birth Groups G1: CHW visitation G2: nurse visitation G3: control Interventions G1: Incremental developmental screening and referral + CHW home visitations G2: Developmental screening and referral + nurse home visitations G3: Developmental screening and referral Group (N) G1: 244 G2: 236 G3: 255 | Title of CHW Paraprofessional Paid or Volunteer Paid Relationship with Community “Shared social characteristics” CHW (N) 10 Supervision of CHW 2 LCSWs (2 supervisors to 10 visitors) Prior Training HS education, no degree in “helping professions”; preferentially prior work experience in human services agencies Type of Service Intensive home visitation: promoting healthy behaviors, competent child care, pregnancy planning, education, employment; linking to social and health services; promoting healthy family/friend relationships Type of Educational Materials Used Visit-specific protocol, adapted to individual needs of mother Duration of Interaction with Clients Every other week (except for weekly visits during first 4 weeks after enrollment and first 6 weeks after delivery) through child’s 21st month, followed by monthly visits during final 3 months, ≈ 75 min per session Length of Follow-up until child 4 y/o | Age (mean) G1: 19.44 G2: 20.24 G3: 19.70 Sex (% female) 100 Race (%) G1: Hispanic: 45%, Caucasian non-Hispanic: 35% African-American: 17% G2: Hispanic: 44% Caucasian non-Hispanic: 37% African-American: 16% G3: Hispanic: 46% Caucasian non-Hispanic: 35% African-American: 16% Other G1 younger and living in denser households than G2 Role of CHW in Recruiting and Retention Recruiting: NR Retention: emphasis on developing continuous relationship between home visitor and subject families Recruitment Rates 62% overall Retention Rates G1: 77% G2: 71% G3: 80% | Knowledge, Attitude, and Behavior: Measure 1 Content of home visit, pregnancy Results Personal health G1 27% G2: 38% (P < 0.001) Environmental health G1 15% G2: 7% (P < 0.001) Life course development G1: 15% G2: 14% (P < 0.05) Parental caregiving G1: 24% G2: 25% Friends/family G1: 19% G2: 15% (P < 0.001) Measure 3 Mother-infant interaction Results Least squares mean G1: 100.15 G2: 100.31 G3: 98.99 G1 vs. G3: 1.16 (−0.11 – 2.42, P < 0.1) G2 vs. G3: 1.32 (0.03–2.60, P ≤ 0.05) Least squares mean difference G1 vs. G2 (low resource group) = 0.06 (01.87 – 1.98), adjusted 0.08 (−1.99 – 2.16) Quality of Life: Measure 1 Home environment Results Least squares mean G1: 37.4 G2: 37.79 G3: 37.1; Mean difference G1–G3: 0.3 (−0.49 – 1.1) G2–G3: 0.69 (−0.12 – 1.5, P < 0.1) Least squares mean difference (low resource group) G1–G2: 0.26 (−0.95 – 1.47), adjusted −0.05 (−1.35 – 1.24) Measure 3 Post-intervention reductino in urine cotinine levels among smokers (ng/mL) Results G1: 89 G2: 259 G3: 12 (NS) Least squares mean difference G1 vs G2: 189.16 (−51.38 – 429.69), adjusted 266.75 (−3.34 – 536.84) Mean difference G1 vs. G3 –76.19 ng/dL (95% CI, −302.21,–149.82) G2 vs. G3 −246.68 ng/dL (95% CI, −466.19,–27.16) P ≤ 0.05 | Health Outcomes: Measure 1 Language @ 21 mo (Preschool Lanaguge Scale) Results Least squares mean G1: 99.89 G2: 101.22 G3: 99.49 Mean difference G1–G3: 0.4 (−1.94 – 2.74) G2–G3: 1.73 (−0.64 – 4.11) Least squares mean (low resource group) G1: 97.83 G2: 101.52 G3: 96.85 Mean difference G1–G3: 0.98 (−2.65 – 4.62) G2–G3: 4.67 (0.85–8.49, Measure 2 Mental development delay @ 24 mo (Mental Development Index) Results Least squares mean G1: 89.45 G2: 90.13 G3: 89.38 Difference G1–G3: 0.07 (−2.39 – 2.53) G2–G3: 0.75 (−1.77 – 3.28) Low resource group: least squares mean G1: 88.54 G2: 90.18 G3: 86.2 Difference G1–G3: 2.33 (−1.46 – 6.12) G2–G3: 3.98 (−0.07 – 8.02) G1–G2 1.26 Measure 1 Subsequent fertility @ 24 mo Results Pregnancy G1: 33% G2: 29% G3: 41% G1–G3: 0.7 (0.46–1.06, P < 0.1) G2–G3: 0.6 (0.39–0.93, P ≤ 0.05) G1–G2: 0.88 (0.57–1.36) G1–G2 (adjusted) = 0.82 (0.51–1.31) Birth G1: 13% G2: 12% G3: 19% G1–G3: 0.63 (0.37–1.07, P < 0.1) G2–G3: 0.58 (0.33–1.01, P ≤ 0.05) G1–G2: 0.9 Healthcare Utilization: NR Measure 2 Maternal life course Results Married G1: 32% G3: 44% (P = 0.02) Living w/bio father G1: 33% G3: 43% (P = 0.03) Working at child 2–4 y/o G1: 15 mo G3: 13 mo (P = 0.04) Sense of mastery G1: 101 G3: 99 (P = 0.03) Mental health score G1: 101 G2: 99 (P = 0.03) No G1–G3 difference on education, welfare Measure 3 Mother-child interaction Results Sensitive responsive interactions during free play G1: 101 G3: 99 (P = 0.03); no difference G2 vs G3 Measure 4 Home environment (Home Observation for Measurement of Environment inventory) Results For low psychologic resource group: environment supportive of early learning G1: 24.63 G2: 24.61 G3: 23.35 (G1–G3 P = 0.03 G2–G3: P = 0.03) | Costs (Economics): Measure 1 Per-family cost over 2.5 years (inflation adjusted, 2002 dollars) Results G2: $6,162 G3: $9,140 Measure 3 Average cost (including salary + benefits, supplies, travel, rent, equipment, training) over approx 2.5 y Results G1: $5,178/family G2: $7,681/family Explanation of Overall Outcomes CHWs were more likely than nurses to discuss environmental health and friends/family, life course development (after pregnancy), and less likely to discuss personal health (during pregnancy) and parental caregiving (after pregnancy); CHWs home visits have little significant effect on maternal & infant health outcomes, except for improved mother-child interactions among low psychological resource subpopulation; CHW visits showed improvement over control in maternal health but not in child health; nurse visit outcomes generally favored child health but not maternal Quality Rating Fair Health Outcomes: NR
Author Year Krieger et al., 1999 Trial Name Seattle Hypertension Intervention Project Objective or Aim Determine whether tracking and outreach intervention delivered by community health workers improved medical follow-up of persons whose elevated blood pressure detected during blood pressure measurement at community sites Geography Seattle Organization Various community sites: social services agencies, food banks, shelters/missions, public libraries, grocery stores, community centers, etc. Type of Community Low-income neighborhoods Study Design RCT Start Date 1994 Duration 28 months | Eligible (N) 759 Enrolled (N) 421 Randomized (N) 421 Completers (N) 397 Withdrawals or Dropouts (N) 110 Health Condition of Interest Hypertension Inclusion Criteria • BP at least 140/90 • 18+ y/o • Black or White race • Income no more than 200% FPL (1995) Exclusion Criteria See inclusion criteria Groups G1: Intervention G2: Usual care Interventions G1: CHW assistance with medical follow-up G2: advice to see medical provider, list of public and community clinics Group (N) G1: 209 G2: 212 | Title of CHW Community health worker Paid or Volunteer NR Relationship with Community Similar income community, predominantly black (12/14) CHW (N) 14 Supervision of CHW NR Prior Training NR Type of Service Medical referral, telephone appt scheduling, appt reminder letter, post-appt f/u, rescheduling missed appt, assistance with other barriers to care (e.g. transportation) Type of Educational Materials Used NR Duration of Interaction with Clients Various, brief interactions over 3 months (time per session NR) Length of Follow-up 3 months | Age (mean) 24.9% < 40 y/o 18.3% > 64 y/o Sex (% female) 27.8 Race (%) 79.1% Black Other 40% uninsured Role of CHW in Recruiting and Retention Providing initial BP measurement Recruitment Rates 55.5% (421 enrolled of 759 eligible) Retention Rates G1: 95% G2: 93% | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: NR Healthcare Utilization: Self-report of completed f/u appt (validated by medical provider report) Results G1: 65.1% completed f/u within 90 days G2: 46.7% (P = 0.001) | Costs (Economics): NR Explanation of Overall Outcomes CHW intervention was associated with significantly higher proportion of subjects completing HTN follow- up exam within 90 days Quality Rating Fair
Author Year Krieger et al., 2002; Krieger et al., 2005^47,48^ Trial Name Seattle-King County Health Homes Project (SKCHH) Objective or Aim Assess effectiveness of a CHW intervention focused on reducing exposure to indoor asthma triggers Geography King Co, Washington Organization Low income urban households Type of Community Low income urban households with child diagnosed with asthma Study Design RCT Start Date 1999 Duration 1 year | Eligible (N) 447 Enrolled (N) 274 Randomized (N) 274 Completers (N) 214 Withdrawals or Dropouts (N) 60 Health Condition of Interest pediatric asthma Inclusion Criteria A household was eligibile if: • home to a child 4–12 years with diagnosed persistent asthma • income < 200% of 1996 federal poverty threshold • child enrolled in Medicaid • caregiver verbally proficient in English, Spanish or Vietnamese • child spent ≥ 50% of nights in house • house was in King County. Exclusion Criteria A child with another chronic illness requiring daily medications; household participation in other asthma case management or care coordination programs in past 2 years; plans to leave King County during next 6 months Groups G1: high intensity G2: low intensity Interventions G1: Initial home environmental assessment and individualized action plans specifying participant and CHES actions to reduce household exposures. CHES made additional visits over 12-month period to provide education and social support, materials to reduce exposures (e.g., bedding covers, vacuums); free allergy testing; advocacy for improved housing conditions. G2: Single CHES visit which consisted of initial environmental assessment, home action plan, limited education, and bedding encasements Group (N) G1: 138 G2: 136 | Title of CHW Community Home Environmental Specialists (CHES) Paid or Volunteer Paid Relationship with Community Connection to and understanding of community; shared ethnic, linguistic, and cultural background with project participants; recognition as a person who can be respected and trusted CHW (N) 6 Supervision of CHW NR Prior Training NR Type of Service home visits Type of Educational Materials Used NR Duration of Interaction with Clients 4 to 9 visits over 12 months (time per session NR) Length of Follow-up 1 year | Age (mean) G1: 7.4 G2: 7.3 Sex (% female) G1: 44.2 G2: 38.2 Race (%) Non-Hispanic White G1: 12.3 G2: 21.3 Non-Hispanic AA G1: 31.9 G2: 27.9 Vietnamese G1: 25.4 G2: 22.1 Other Asian G1: 9.4 G2: 5.2 Hispanic G1: 17.4 G2: 17.7 Other G1: 3.6 G2: 5.9 Other Household had at least 1 asthma trigger: 75% Urgent health use in past 2 months (%) G1: 25.9 G2: 21.3 Smoker in home (%) G1: 39.9 G2: 41.9 Severe persist asthma G1: 32.6 G2: 23.5 Role of CHW in Recruiting and Retention Cannot determine Recruitment Rates NR Retention Rates G1: 80% G2: 76% | Knowledge, Attitude, and Behavior: Measure 1 Behavior summary score of trigger reduction behaviors (vacuum and dust child's bedroom at least twice/2 weeks, vacuum cloth-covered furniture at least twice/2 weeks or remove it, use doormat or remove shoes, use allergy control covers on mattress and pillow Results Across groups comparison: GEE coefficient (95% CI): 0.41 (−0.13, 0.95); P = 0.141 frequencies of actions to reduce dust exposure and use of bedding encasements increased more in high-intensity group. Kitchen ventilation improved more in low-intensity group. Neither group increased frequency of washing sheets or dusting nor reduced exposure to pets (although pet ownership was uncommon among participants) and smoking in home. behavior summary score improved in both groups, and across-group difference was not significant Quality of Life: Measure 1 Pediatric Asthma Caregiver Quality of Life Scale (score range 1–7 with higher scores indicating better QoL) Results Score at exit (G1 vs. G2): 5.6 vs. 5.4 GEE coefficient 0.58 (95% CI, 0.18, 0.99), P = 0.005; NNT = 4.8 ITT analysis yielded simalr results: improvements in QoL were greater in G1 (data NR, P = 0.009) Measure 2 Asthma symptom days (self-reported # of 24- hour periods during 2 weeks before interview with asthma symptoms: wheeze, tightness in chest, cough, shortness of breath, slowing down activities due to asthma, nighttime awakenings) Results G1 vs. G2 at exit: 3.2 vs. 3.9 GEE coefficient -1.24 (95% CI, −2.9, 0.4), P = 0.138 | Health Outcomes: Measure 1 Days with activity limitation/2 weeks Results Score at exit (G1 vs. G2): 1.5 vs. 1.7 GEE coefficient -1.5 (95% CI, −2.84, – 0.15), OR 0.22 (0.06, 0.86), P = 0.29 Measure 2 Missed school in past 2 weeks (%) Results G1 vs. G2 at exit: 12.2 vs. 20.3 GEE coefficient -0.77 (95% CI, −1.70, 0.16), OR 0.46 (0.18, 1.18), P = 0.105 Measure 3 Urgent health services use/2 months (%) Results G1 vs. G2 at exit: 8.4 vs. 16.4 GEE coefficient -0.97 (95% CI, −1.8, – 0.12), OR 0.38 (0.16, 0.89), P = 0.026; NNT = 12.9 ITT analysis yielded simalr results: improvements in urgent health services were greater in G1 (data NR, P = 0.062) Measure 4 Days used controller medication/2 weeks Results G1 vs. G2 at exit: 3.5 vs. 3.6 GEE coefficient -1.03 (95% CI, −2.79, 0.73), P = 0.250 Measure 5 Days used beta2-agonist/2 weeks Results G1 vs. G2 at exit: 4.0 vs. 4.0 GEE coefficient -0.23 (95% CI, −1.88, 1.42), P = 0.781 Measure 6 Missed work in past 2 weeks (%) Results G1 vs. G2 at exit: 11.2 vs. 13.0 GEE coefficient 0.07 (95% CI, −0.91, 1.0.5), OR 1.07 (0.40, 2.85), P = 0.890 Healthcare Utilization: NR | Costs (Economics): Measure 1 Urgent care costs (hospital admissions, ER visits, unscheduled clinic visits) Results Two months before exit interview G1 $6301–$8856 ($57–$80/child) less than G2. Estimated decrease in 2 month costs between baseline and exit: G1: $22084–$36700 ($201–$344/child) vs. G2: $19246–$32756 ($185–$315/child) Explanation of Overall Outcomes NR Quality Rating Good Health Outcomes:
Author Year Levine et al., 2003 Trial Name NR Objective or Aim Compare program effectiveness and intervention efficacy of more and less intensive education/behavior interventions on control of SBP Geography Sandtown- Winchester Community, Baltimore Organization inner city Type of Community Urban African- American Study Design RCT Start Date NR Duration 30 months | Eligible (N) 817 Enrolled (N) 789 Randomized (N) 789 Completers (N) 471 Withdrawals or Dropouts (N) 318 Health Condition of Interest Hypertensive heart disease Inclusion Criteria African-American adults w/HTN (140+/90+) Exclusion Criteria • Terminal conditions • Mental impairment • Acute conditions precluding participation Groups G1: More intense intervention G2: Less intense intervention Interventions G1: G2 care + 5 CHW visits with BP measurement, addressing issues of BP management and access to medical care G2: CHW home visit for education, counseling, and referral Group (N) G1: 387 G2: 402 | Title of CHW Community health worker Paid or Volunteer NR Relationship with Community Indigenous to community CHW (N) NR Supervision of CHW Nurse-supervised Prior Training NR Type of Service Home visits; BP measurement; education; assistance with access to care Type of Educational Materials Used Counseling; BP tracking card; educational pamphlet Duration of Interaction with Clients 6 visits over 2.5 years (length per visit NR) Length of Follow-up 40 mo | Age (mean) G1: 53.8 G2: 54.6 Sex (% female) G1: 61.2 G2: 62.5 Race (%) 100'% African-American Other • HS-level education: 42% • < HS: 45% • Unemployed: 32% • Income < $10k: 65% • With usual source of care: 79% • Uninsured: 20% Role of CHW in Recruiting and Retention • Initial neighborhood surveillance • Recruiting for individual RCT Recruitment Rates 0.97 Retention Rates G1: 240/387 = 62% G2: 231/402 = 57% | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: Measure 1 BP change (unadjusted systolic/diastolic ± SE; adjusted systolic/diastolic ± SE) Results G1: −5.5±1.5/−4.1±0.9; 5.6±1.5/−3.8±1.0) G2: −3.2±1.5/−2.9±1.0; −3.3±1.5/−2.6±1.0 ) P < .005 for differences between baseline and followup for each group, no differences between groups Measure 2 % with adequate HTN control ( < 140/90) Results G1: 16% → 36% G2: 18% → 34% pre/post P < .01 group difference NS Measure 3 Pre/post BP (systolic/diastolic) Results G1: 147.7/89.2 (95% CI, 145.5, 149.9/87.8, 90.6) → 145/86.2 (95% CI, 142.3, 147.7/84.2, 88.2) G2: 148.6/89.3 (95% CI, 146.4, 150.7/87.8, 90.8) → 142.1/84.7 (95% CI, 138.8, 145.4/82.7, 86.7) P < 0.05 for differences between baseline and followup for eachHealthcare Measure 4 JNC-VI classification pre/post Results No significant differences Utilization: NR | Costs (Economics): NR Explanation of Overall Outcomes CHW intervention produced significant pre/post change in proportion of HTN under control in both arms, but no difference between arms; no significant pre vs post change in BP classification within or between arms; more intensive group had less favorable results than less intensive group Quality Rating Fair Health Outcomes: NR
Author Year Lujan; 2007 Trial Name NA Objective or Aim Determine effectiveness of intervention led by promotoras on glycemic control, diabetes knowledge and diabetes health beliefs of Mexican- Americans with type 2 DM living on Texas-Mexico border Geography Texas-Mexico border city Organization Mexican Americans at a Catholic faith- based community clinic Type of Community Type 2 diabetes mellitus Study Design RCT Start Date NR Duration NR | Eligible (N) 160 Enrolled (N) 150 Randomized (N) 150 Completers (N) 141 Withdrawals or Dropouts (N) 9 Health Condition of Interest Diabetes mellitus type 2 Inclusion Criteria 40+ years, self-reported Mexican American ethnicity, diagnosed with type 2 diabetes for at least 1 year, taking or having taken hypoglycemic agents within past 6 months, willing to participate, noncompletion of formal diabetes education program at clinic, ability to speak either English or Spanish, only 1 per household Exclusion Criteria Type 1 diabetes, younger than 40 years, diagnosed with diabetes for less than 1 year, being treated for complciations that would interfere with ability to participate in classes Groups G1: Promotoras G2: Usual Care Interventions G1: A team of 2 promotoras delivered 8 weekly, 2 hour participative group classes and follow-up to intervention group, using multiple visual audio teaching aides and handouts, contacted class participants by phone biweekly to answer questions, reinforce education, promote behavior change, sent postcards biweekly G2: Usual care by clinic staff - verbal information and 1 or 2 pamphlets on diabetes self-management Group (N) G1: 75 G2: 75 | Title of CHW Community lay workers (promotoras) Paid or Volunteer paid Relationship with Community bilingual clinic employees CHW (N) NR Supervision of CHW PI attended every class Prior Training NR Type of Service Classroom: 8 weekly 2- hour group classes; Biweekly Telephone calls Type of Educational Materials Used Developed by certified health educator with promotoras, based on ADA Guidelines Duration of Interaction with Clients 8 weekly 2-hour classes + biweekly telephone calls for 8 weeks followed by biweekly postcards for 16 weeks 24 weeks total duration of interaction with participants Length of Follow-up 6 months | Age (mean) 58 years Sex (% female) 80 Race (%) 100% Mexican American Other • Without health insurance: 68% • Preferred to speak Spanish: 97% • Catholic: 74% Role of CHW in Recruiting and Retention Unclear Recruitment Rates NA Retention Rates G1: 71 G2: 70 (at 6 months) | Knowledge, Attitude, and Behavior: Measure 1 Bilingual DKQ - validated: 24 itms designed for Mexican Americans and elicits information about respondent's understanding of cause of diabetes, types of diabetes, self- management skills, and complications of diabetes Results Baseline/6 months (SD): G1: 69.1 (13.6)/77.2 (14.4) G2: 66.9 (15.2)/65.1 (21.0) (P < .002 for mean change between groups) Measure 2 Diabetes Health Belief Measure (DHBM) Results Baseline(SD)/6 months(SD): G1: 56.4(12.2)/54.6(8.4) G2: 57.0(10.6)/50.8(13.6) Mean change between groups: P < 0.01 Quality of Life: NR | Health Outcomes: Measure 1 HgbA1c Results Baseline(SD)/6 months(SD): G1: 8.21(2.2)/7.76(1.87) G2: 7.71(1.47)/8.01(1.8) Mean change between groups: P < 0.001 Measure 3 HgbA1c - validated Results At 6 months: G1: 7.76 G2: 8.01 (P < .001) Healthcare Utilization: NR | Costs (Economics): NR Explanation of Overall Outcomes NR Quality Rating Good
Author Year Mock et al., 2007 Trial Name Vietnamese REACH for Health Initiative Objective or Aim Increase cervical cancer screening rates Geography Santa Clara County, CA Organization Commnity Type of Community Vietnamese American women Study Design RCT Start Date 2001 Duration 3 years | Eligible (N) NR Enrolled (N) 1005 Randomized (N) NR Completers (N) 968 Withdrawals or Dropouts (N) 37 Health Condition of Interest Pap screening Inclusion Criteria • Vietnamese American • Female • ≥18 years • Living in Santa Clara County Exclusion Criteria NR Groups G1: CHW + media G2: media only Interventions G1: CHW small group meetings, direct contact with subjects, Vietnamese language ads for TV/radio/newspaper, booklets and printed materials in various community locations G2: Vietnamese language ads for TV/radio/newspaper, booklets and printed materials in various community locations, delayed educational session Group (N) G1: 491 G2: 477 | Title of CHW Lay health worker Paid or Volunteer Paid, $1500 Relationship with Community Shared race/ethnicity, physical community CHW (N) 50 Supervision of CHW Non clinician Prior Training NR Type of Service Small group gatherings, direct contacts to help access medical services and schedule appts Type of Educational Materials Used Prepared presentation with flip chart, QandA Duration of Interaction with Clients 2 sessions of 90 or 120 minutes each plus individual contacts over 3 to 4 months Length of Follow-up 3–4 months | Age (mean) G1: 45.7 G2: 46.0 Sex (% female) G1: 100 G2: 100 Race (%) Vietnamese 100 Other Mean years in US G1: 8.92 G2: 9.23 Self-rated speaking English poorly/not at all G1: 56.3% G2: 57.7% > HS education G1: 57.5% G2: 54.8% Married G1: 61.3% G2: 64.3% Employed G1: 26% G2: 27.1% Role of CHW in Recruiting and Retention CHW recruited subjects from within her own social network Recruitment Rates G1: 100% G2: 100% Retention Rates G1: 97.8% G2: 94.8% | Knowledge, Attitude, and Behavior: Measure 1 Reported awareness of need for Pap by women 18+ y/o Results G1: 68.4→93.9% (P < 0.001) G2: 68.5→70.2% (P = 0.55); Z-test P < 0.001) Measure 2 Reported awareness of need for pap test by women 18+ years old Results G1: 81.8%/99.6% (P < 0.001) G2: 87.2%/95.2% (P < 0.001) Z-test P < 0.001 Quality of Life: NR | Health Outcomes: NR Healthcare Utilization: Measure 1 Self-report of Pap in past year Results G1: 45.7→67.3% (P < 0.001) G2: 50.9→55.7% (P = 0.035); Z test P < 0.001 Measure 2 Ever had Pap test (among those who had not had Pap test preoutreach) Results G1: 46.0 (N = 144) G2: 27.1 P < .001 (N = 161) Measure 3 Self-report of having ever had Pap Results G1: 65.8→81.8% (P < 0.001) G2: 70.1→75.5 (P < 0.001); Z test P = 0.001 | Costs (Economics): NR Explanation of Overall Outcomes CHW + media intervention significantly increases understanding of and utilization of Pap compared to media intervention alone Quality Rating Fair
Author Year Morisky et al., 2002; Ward et al., 2000 Trial Name Community Hypertension Intervention Project (CHIP) Objective or Aim Develop effective strategies for enhancing treatment adherence for hypertensive minority populations Geography Large West Coast city Organization County medical center Type of Community Low-income, inner- city Blacks and Hispanics Study Design RCT Start Date NR Duration 4 years | Eligible (N) NR Enrolled (N) 1367 Randomized (N) 1367 Completers (N) NR Withdrawals or Dropouts (N) NR Health Condition of Interest Hypertension Inclusion Criteria Adult w/diagnosis of HTN attending county hospital clinic or private health clinic Exclusion Criteria NR Groups G1: Individualized CHW pt counseling G2: Appt tracking G3: CHW home visits + voluntary discussion group attendance G4: Usual care Interventions G1: CHW post-clinic appt counseling session G2: Appt reminder cards and phone calls G3: Home visits by CHW G4: Standard clinic care Group (N) G1: 330 G2: 328 G3: 333 G4: 328 | Title of CHW Community health worker Paid or Volunteer NR Relationship with Community Same ethnic group as patient, language concordant CHW (N) NR Supervision of CHW NR Prior Training 1 month interview training program Type of Service Counselling after clinic visits, or home visits Type of Educational Materials Used Education on treatment, lifestyle modification info, info on community resources Duration of Interaction with Clients G1: 5–10 min after each clinic visit G3: variable Number of visits, duration per session, time period over which interactions occurred NR Length of Follow-up 12 mo | Age (mean) 53.5 (SD 12.0) Sex (% female) 59.2 Race (%) Black: 77% Hispanic: 21% Other • < HS education: 49% • Married: 33% • Income < $14k/y: > 87% • Public insurance: 54% • Uninsured: 30% Role of CHW in Recruiting and Retention Interviews with new enrollees Recruitment Rates > 98% overall Retention Rates NR | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: Measure 1 BP Control Results G1: 35.2% @ baseline, 46% @ 6 and 12 mo (P < 0.01) G2: 40.2% @ baseline 42% @ 6 mo 48% @ 12 mo (P < 0.01) G3: 29.7% @ baseline %NR but “improved” @ 6 & 12 mo G4: 36.9% @ baseline % NR but “improved” No significant differences vs. control - all groups improved Healthcare Utilization: NR | Costs (Economics): NR Explanation of Overall Outcomes NR Quality Rating Poor
Author Year Nacion et al., 2000 Trial Name REACH-Futures Objective or Aim Can maternal-child health advocates, working with professional nurses, provdie health screening, problem identification, self and infant care information, and referrals in a safe manner? Geography Chicago Organization inner city Type of Community Predominantly African-American and Latino Study Design Retrospective cohort Start Date 1992 Duration 32 mo | Eligible (N) 218 Enrolled (N) 213 Randomized (N) 213 Completers (N) 213 Withdrawals or Dropouts (N) 0 Health Condition of Interest Maternal and child health Inclusion Criteria Home visit accomplished by CHW with validating follow-up by nurse Exclusion Criteria Visit conducted by CHW + nurse together Groups G1: CHW visit G2: nurse visit Interventions NR Group (N) G1: 213 G2: 213 | Title of CHW Maternal-Child Health Advocate Paid or Volunteer Paid Relationship with Community Within community, minority CHW (N) 11 Supervision of CHW Validation by nurse after each visit Prior Training Minimum HS or GED; experience in community service Type of Service Intensive home visits for assessment, problem solving, emotional support, and information Type of Educational Materials Used NR Duration of Interaction with Clients NR Length of Follow-up NR | Age (mean) 58% 20+ y/o Sex (% female) 100 Race (%) • African-American: 90% • Latina: 9% Other • < HS education: 51% • Gravida-1: 53% Role of CHW in Recruiting and Retention NA - CHW visits were unit of analysis Recruitment Rates NA - CHW visits were unit of analysis Retention Rates NA - CHW visits were unit of analysis | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: NR Healthcare Utilization: Measure 1 Agreement in identifying problems Results CHW more likely to identify problems in woman's health (P =0.01), well child health care deficits (P = 0.02), parenting (P = 0.02), socioeconomic (P < 0.01); most visits identified no problems Measure 2 Agreement in placing referrals Results Nurse more likely to make referrals for woman's health (P = 0.01), well woman (P = 0.02), emotional/interpersonal, parental support, and socioeconomic (P < 0.01); most visits involved no referrals Measure 3 Services provided (per completed Maternal-Child Activity form) Results Problem solving G1: 16% G2: 7% (P < 0.01) Emotional support G1: 4% G2: 14% (P < 0.01) Assessment, information: No difference between groups | Costs (Economics): NR Explanation of Overall Outcomes • CHW and nurse home visits were comparable in most regards • CHW more likely to identify problems and provide problem solving • Nurse more likely to provide referrals and emotional support Quality Rating Fair
Author Year Navarro et al., 1998; Navarro et al., 1995; Navarro et al., 2000 Trial Name Por La Vida Damos Cuenta Program Objective or Aim To describe impact of intervention known as Por La Vida (PLV) on cancer screening for Latinas in San Diego, California Geography Southeast area of San Diego County, CA Organization Low-income Latino communites Type of Community Low-income Latino women Study Design RCT Start Date NR Duration NR | Eligible (N) NR Enrolled (N) 512 Randomized (N) 512 Completers (N) 365 Withdrawals or Dropouts (N) 147 Health Condition of Interest Breast and cervical cancer Inclusion Criteria Part of social network of consejeras recruiting participants. No other inclusion criteria reported. Exclusion Criteria NR Groups G1: Lower intensity CHW intervention G2: Higher intensity CHW intervention Interventions G1: CHW delivering Community Living Skills sessions, details NR G2: CHW delivering Cancer education sessions, 12 weekly group sessions conducted over 3- months plus 2 additional sessions offered within a year of beginning of group meetings Group (N) G1: 18 consejeras, 238 women G2: 18 consejeras, 274 women | Title of CHW Consejeras Paid or Volunteer NR Relationship with Community Member of Latino community perceived, as "natural helpers" by community CHW (N) 36 Supervision of CHW Yes--"unobtrusive observations" of ongoing sessions and debriefing sessions with consejeras each month by PLV "staff" but no reporting of who these staff members are Prior Training NR Type of Service Small group educational sessions Type of Educational Materials Used Pamphlets, work sheets, posters, plastic models of female body, pelvic models Duration of Interaction with Clients 12 sessions of 90 minutes each over 3 months Length of Follow-up 3 months 1 and 2 year followup | Age (mean) • Average: 34 • Range: 18-72 Sex (% female) 100 Race (%) Latina: 100 Other • Median gross family income: $12,000 • Median years of formal education: 7 • Born in Mexico: 92% • Avg acculturation: 2 Role of CHW in Recruiting and Retention CHW recruited all participants through social networks Recruitment Rates 1 Retention Rates G1: 68.1 G2: 72.6 | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: Measure 1 Pretest-posttest changes in % of women performing monthly BSEs Results Participant unit of analysis (n = 361) G1: 18.5 G2: 33.2 P < 0.001 t = 3.23 Consejera unit of analysis (n = 35) G1: 18.6 G2: 31.8 P = 0.021 t = 2.43 Measure 3 Pretest-posttest changes in % of women 40 yrs who had mammogram within past year Results Participant unit of analysis (n = 113) G1: 7 G2: 21.4 P = 0.029 t = 2.22 Consejera unit of analysis (n = 33) G1: 6.8 G2: 24.3 P = 0.063 t = 1.96 Healthcare Utilization: Measure 1 Pretest-posttest changes in % of women who had physical breast exam within past year Results Participant unit of analysis (n = 359) G1: 15.5 G2: 17.7 P = 0.589 t = 0.54 Consejera unit of analysis (n = 35) G1: 19.3 G2: 19.5 P = 0.967 t = 0.04 Measure 2 Pretest-posttest changes in percentages of women who had a Pap test within past year Results Participant unit of analysis (n = 360) G1: 16.2 G2: 23.1 P = 0.096 t = 1.67 Consejera unit of analysis (n = 35) G1: 18.4 G2: 23.4 P = 0.369 t = 0.91 | Costs (Economics): NR Explanation of Overall Outcomes Increase in use of cancer screening tests higher in PLV cancer intervention group compared to community living skills (control) group Results from 1 and 2 yr followup suggest that cancer screening rates in Latinas of low socio- economic level with limited a Quality Rating Poor Health Outcomes: Measure 1 Odds of montly BSE 1 yr and 2 yr followup for cancer screening group (P value) Results Year 1: 2.03 (.016) Year 2: 0.96 (.877) Measure 2 Odds of CBE 1 yr and 2 yr followup for cancer screening group (P value) Results Year 1: 1.21 (.556) Year 2: 1.93 (.038) Measure 3 Odds of mammogram 1 yr and 2 yr followup for cancer screening group (P value) Results Year 1: 1.50 (.484) Year 2: 3.88 (.018) Measure 4 Odds of pap smear 1 yr and 2 yr followup for cancer screening group (P value) Results Year 1: 2.10 (.017) Year 2: 1.70 (.082)
Author Year Parker et al., 2008 Trial Name Community Action Against Asthma (CAAA) Objective or Aim Evaluate a CHW intervention to improve children's asthma-related health by reducing household environmental triggers for asthma Geography Eastside and southwest Detroit, MI Organization Urban households with children attending neighborhood elementary schools Type of Community Urban neighborhoods with child with asthma Study Design RCT Start Date 2000 Duration 1 year | Eligible (N) 510 Enrolled (N) 328 Randomized (N) 328 Completers (N) 227 Withdrawals or Dropouts (N) 101 Health Condition of Interest pediatric asthma Inclusion Criteria Child 7-11 years with persistent asthma (defined as any of following being true: one or more daytime symptoms reported as being present “more than two times per week,”; sleep disturbance reported “more than two times per week”; and daily use of doctor-prescribed medicine for respiratory symptoms) living in southwest or eastside Detroit Exclusion Criteria Children who lived outside of defined geographic area or were monolingual in a language other than Spanish or English were excluded from study. Groups G1: CHW G2: Control Interventions G1: Environmental assessment; asthma action plan based on allergy tests; education and social support; social support; mattress covers, pillows, vacuum, cleaning supplies; counseling on environmental tobacco smoke; integrated pest management services; minimum 9 planned home visits over 12 months G2: Asthma information booklet, full intervention after 12 months Group (N) G1: 150 G2: 148 | Title of CHW CES Paid or Volunteer NR Relationship with Community Detroit residents; 2 were bilingual (Spanish and English) CHW (N) 4 Supervision of CHW NR; however, there was a steering committee of community members, health agencies, etc. involved in project; also CHWs had continued training throughout intervention period Prior Training NR Type of Service home visits Type of Educational Materials Used Written materials on on dangers of ETS exposure for children with asthma Global Initiative for Asthma booklet Duration of Interaction with Clients At least 9 visits over 12 months (time per session NR Length of Follow-up 1 year | Age (mean) G1: 9.01 G2: 8.8 Sex (% female) G1: 43 G2: 41 Race (%) African American G1: 83 G2: 79 Hispanic G1: 11 G2: 10 Caucasian G1: 4 G2: 5 Other G1: 3 G2: 6 Other Caregiver smokers (%) G1: 40 G2: 35 Moderate-severe persistent asthma G1: 51 G2: 44 Household income < $10000 G1: 37 G2: 46 Role of CHW in Recruiting and Retention No role; CES was assigned cases Recruitment Rates NA Retention Rates G1: 77% G2: 75% (Does not include 30 postrandomization exclusions) | Knowledge, Attitude, and Behavior: Measure 1 Behavior to reduce asthma triggers in house Results Intervention Effect (OR- intervention/OR-control) Vacuum cleaner used: 29.5 (6.90, 126); P < 0.0001 Allergen cover on child's pillow: 19.7 (4.12, 94.2); P = 0.0006 Allergen cover on child's mattress: 9.70 (4.33, 21.7); P < 0.0001 Visible mold growth remo Measure 3 Caregiver depressive symptoms measured by CES-D Results Mean @ Baseline/Endpoint G1: 1.62/1.54 G2: 1.58/1.64 P = 0.0218 Improvements in both instrumental and emotional social support combined and instrumental support alone were not statistically significant (data NR) Quality of Life: NR | Health Outcomes: Measure 1 Child's average asthma symptom frequency Results G1: Symptoms occurring less frequently at baseline for all eight symptoms assessed G2: Symptoms occurring less frequently for 6 of 8 Persistent cough baseline, post-intervention: G1: 3.81, 3.36 G2: 3.48, 3.44 P = 0.034 Cough w/ exercise baseline, post: G1: 4.27, 3.69 G2: 3.80, 3.66 P = 0.017 Healthcare Utilization: Measure 1 Has any symptom more than 2 days/week and not on a corticosteroid Results G1 (pre/post) vs. G2 (pre/post) Intervention Effect (95% CI): 60/42 vs. 51/46; 0.56 (0.29, 1.06); P = 0.073 Measure 2 Has any symptom more than 2 days/week and not on any controller Results G1 (pre/post) vs. G2 (pre/post) Intervention Effect (95% CI: 53/32 vs. 38/37; 0.39 (0.20, 0.73); P = 0.004 Measure 3 Reduction in unscheduled health care utilization for asthma Results Needed unscheduled medical care G1 (pre/post) vs. G2 (pre/post) Intervention Effect (95% CI): In last 12 months: 65/59 vs. 58/73; 0.40 (0.22, 0.74); P = 0.004 In last 3 months: 50/45 vs. 42/56; 0.43 (0.23, 0.80); P = 0.007 | Costs (Economics): NR Explanation of Overall Outcomes NR Quality Rating Fair
Author Year Paskett et al., 2006; Katz et al., 2007 Trial Name ROSE (Robeson County Outreach Screening and Education) Objective or Aim To use LHAs to deliver individualized health education to improve rates of mammography screening Geography Robeson County, NC Organization Community health centers - Robeson Health Care Corporation (federally funded, four centers) Type of Community County Study Design RCT Start Date February 1998 Duration 4 years | Eligible (N) 1,503 Enrolled (N) 901 Randomized (N) 897 Completers (N) 820 Withdrawals or Dropouts (N) 77 Health Condition of Interest Breast cancer screening Inclusion Criteria Women without a mammogram in past 12 months Exclusion Criteria Mentally or physically unable to participate, unreachable, language/hearing barrier Groups G1: Control G2: Intervention Interventions G1: Control sent letter and NCI brochure about need for regular cervical cancer screening 6 months after random assignment, followed by letter and NCI brochure about need for mammography 3 months after follow-up assssment G2: Individualized health education program that was culturally acceptable and tailored to meet needs of each woman, intensive face-to-face interactive educational program administered over a 9- to 12 month period, consisting of 3 in-person visits, with educational materials provided each visit and follow-up phone calls and mailings after Group (N) G1: 444 G2: 453 | Title of CHW Lay health advisor Paid or Volunteer Paid Relationship with Community Ethnicity: 2 native American and 1 African-American CHW (N) 3 Supervision of CHW LHA supervisor checked in weekly by phone or in- person to discuss cases and problems; periodic attendance of LHA supervisor during patient visits Prior Training 1 nurse, 1 social worker, 1 research study interviewer Type of Service home visits, phone calls Type of Educational Materials Used written, culturally sensitive Duration of Interaction with Clients Two visits, 45-60 minutes, and 30-45 minutes, two intervening telephone calls, and a final visit (duration of final visit NR) over 9 to 12 months Length of Follow-up 14 months | Age (mean) 55.1 Sex (% female) 100 Race (%) • African-American: 33% • Native American: 42% • White: 25% Other NR Role of CHW in Recruiting and Retention NA Recruitment Rates NA Retention Rates NA | Knowledge, Attitude, and Behavior: Measure 1 Composite belief scores (higher is better) Results G1: 6.95 G2: 7.55 (P = 0.004) Measure 2 Composite knowledge scores Results Specific scores NR, P value for G1 = 0.002, G1 < 0.001, no statistically significant differences Quality of Life: NR | Health Outcomes: NR Healthcare Utilization: Measure 1 Cervical cancer screening rates within risk-appropriate guidelines Results Significant differences between baseline and followup for both groups, no significant differences between intervention and control groups Measure 2 Mammogram receipt from medical record data Results G1: 27.3% G2: 42.5%, RR = 1.56, 95% CI, 1.29 to 1.87, P < .001; significant differences within racial groups as well Measure 3 Intervention cost divided by additional mammograms in LHA group compared with usual care Results $4,986 per additional mammogram in LHA group | Costs (Economics): NR Explanation of Overall Outcomes NR Quality Rating Good
Author Year Pilote et al., 1996 Trial Name NR Objective or Aim Peer health advisers familiar with homelessness and ways of street could facilitate access to health care for TB in a homeless population. Geography San Francisco, CA Organization Homeless population Type of Community Lack of neighborhood (homeless) Study Design RCT Start Date June 1992 Duration 23 months | Eligible (N) 297 Enrolled (N) 244 Randomized (N) 244 Completers (N) 173 Withdrawals or Dropouts (N) 71 Health Condition of Interest TB Inclusion Criteria Homeless men and women, PPD positive Exclusion Criteria recent follow-up Groups G1: Peer health advisor G2: Monetary incentive G3: Usual care Interventions G1: Peer health advisor-met with patient and took them to clinic appointment, facilitated paperwork, reviewed physician recommendations G2: Monetary incentive - $5 at clinic, appointment and bus tokens G3: Usual care - appointment and bus tokens Group (N) G1: 83 G2: 82 G3: 79 | Title of CHW Peer health adviser Paid or Volunteer Paid Relationship with Community Also homeless CHW (N) 7 Supervision of CHW NR Prior Training NR Type of Service Took client to clinic and helped with proccess Type of Educational Materials Used None Duration of Interaction with Clients NR - met client and went to clinic within a 3 week period (duration of session NR) Length of Follow-up 3 weeks | Age (mean) Median G1: 40 G2: 39 G3: 40 Sex (% female) G1: 13 G2:19 G3:16 Race (%) G1: African American: 48 White: 33 Hispanic: 16 G2: African American: 57 White: 27 Hispanic: 11 G3: African American: 54 White: 27 Hispanic: 13 Other Role of CHW in Recruiting and Retention NR Recruitment Rates NR Retention Rates NR | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: NR Healthcare Utilization: Measure 1 Adherence to first follow-up appointment % (95% CI) P versus usual care - unclear how obtained Results G1: Peer health advisor 75 (70–80) P = 0.004 G2: Monetary incentive 84 (76–92) P < 0.001 G3: Usual care 53 (47–59) | Costs (Economics): NR Explanation of Overall Outcomes Quality Rating Fair
Author Year Rask et al., 2001; LeBaron et al., 2004^63^ Trial Name NA Objective or Aim (1) Prospectively measure costs of 3 different registry-based interventions implemented in an urban indigent population and (2) evaluate how size of targeted population affects cost estimates Geography Fulton County, GA Organization MATCH (Metro Atlanta Team for Child Health) immunization registry: community-based partnership between two county health agencies, local nonprofit, federally qualified community health centers Type of Community See prior Study Design RCT Start Date 1996 Duration 22 months (35 mo for follow-up contact; 53 months for electronic acquisition of vaccine information) | Eligible (N) 3050 Enrolled (N) 3050 Randomized (N) 3050 Completers (N) NR Withdrawals or Dropouts (N) 304 not exposed to intervention (within intervention arms) Health Condition of Interest Pediatric immunizations Inclusion Criteria Children aged < 12 months seen in a county public health clinic Exclusion Criteria NR Groups G1: AUTODIAL G2: OUTREACH worker G3: combination of 1 and 2 G4: CONTROL Interventions G1: Autodial-received an automated telephone call or postcard to remind families 7 calendar days before child was due to be immunized. Patient received postcard if no number or nonworking. Delivered recorded message from head medical staff. G2: Outreach - contacted by outreach worker following a standardized protocol initated by a phone call wihtin 1 week. outreach worker made reminder call before appt if time known. if child remained behind next monht, a home visit was attempted monthly until contact was made. Group (N) G1: 763 G2: 760 G3: 764 G4: 763 | Title of CHW Outreach worker Paid or Volunteer NR Relationship with Community •African American woman raised in inner-city Atlanta •Bilingual Hispanic worker CHW (N) 2 Supervision of CHW Doctorate in community psychology and extensive experience in conducting inner-city studies Prior Training College-educated Type of Service Phone calls, home visit for appointment reminder, assistance in overcoming barriers to appointment for pediatric immunizations if needed Phone calls, home visits Type of Educational Materials Used NR Duration of Interaction with Clients At least one telephone call, followed by repeat calls and home visit if no telephone contact, over 15 months or less (time per interaction NR) Length of Follow-up 15 months | Age (mean) 9 months Sex (% female) 51 Race (%) 93% minority (black or Hispanic) Other NR Role of CHW in Recruiting and Retention NR Recruitment Rates NR Retention Rates NR | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: Measure 1 Vaccine Series complete from immunization registry Results No statistical difference between CHW and control groups Healthcare Utilization: NR | Costs (Economics): Measure 1 Average monthly costs to dleiver immunization interventions per child Results G1: $1.34 G2: $1.87 G3: $2.76 Explanation of Overall Outcomes NR Quality Rating Good
Author Year Sauaia et al., 2007; Welsh et al., 2005 Trial Name Tepeyac Project Objective or Aim To increase breast cancer screening rates among Latinas in Colorado;64 To compare effect of promotora vs printed statewide interventions on mammogram rates of Latinas and non-Latina whites (NLWs) enrolled in Medicaid fee-for-service program 65 Geography Colorado Organization Catholic Churches, Latina Women Type of Community Church communities Study Design Retrospective cohort Start Date 2000 Duration 5 yrs | Eligible (N) •Latina only analysis: 4,739;^64^ •Latina vs. white analysis: 6,696^65^ Enrolled (N) NA Randomized (N) NA Completers (N) Latina only analysis: 4739^64^; Latina vs. white analysis: 6696^65^ Withdrawals or Dropouts (N) NA Health Condition of Interest Breast cancer screening Inclusion Criteria Latina only analysis: •Latinas (identified through race and ethnicity data combined with surnames) •Aged 50 to 69 years •Continuously enrolled in insurance plan (Medicaid or Medicare) for longer than 23 months with no gap in coverage longer than 30 days •Survived entire baseline or follow-up period64 Latina vs. white comparison: •White or Latina women (identified through race and ethnicity data) •Aged 50–64 years •Enrolled in CO Medicaid at least 18 mo during baseline and follow-up periods65 Exclusion Criteria NR Groups G1: Promotora Intervention - study subjects living in zip codes of churches visited by promotoras during 2000 and 2001 G2: Printed intervention - Subjects living in remaining zip codes Interventions G1: Trained peer counselors (Promotoras) delived health promotion message personally, through meetings held at least bimonthly immediately after mass and through other church events, conducted health groups that met at home of one of participants, same newsletter used in printed Intervention G2: Printed intervention incorporated into church display, bulletin and/or pulpit announcements Group (N) Latina only analysis G1: 4 churches, N at baseline: 536, N at followup: 590 G2: 209 churches, N at baseline: 5130, N at followup: 5708;^64^ Latina vs. white analysis G1: 4 churches, N at baseline: 197, N at followup: 211 G2: 209 churches, N at baseline | Title of CHW Promotora (peer counselors) Paid or Volunteer Paid Relationship with Community Shared community and ethnicity CHW (N) NR Supervision of CHW NR Prior Training NR Type of Service Peer “approach” after Sunday mass and during church-related activities; facilitation of home discussion groups Type of Educational Materials Used •Letter describing project •Bilingual printed materials from NCI that promote breast ca screening and reflect a sense of family •Display unit •Short bilingual messages suitable for delivery from pulpit and publication in church bulletins Duration of Interaction with Clients At least bimonthly meetings(length NR) over 5 years Length of Follow-up NA | Age (mean) Latina only analysis: Not specified;64 Latina vs. white analysis G1: Latina 59 (SD 4.1); non-Latina 57.5 (4.3) G2: Latina 58.4 (4.4); non-Latina 57.9 (4.5)65 Sex (% female) 100 Race (%) Latina only analysis: 100% Latina;64 Latina vs. white analysis G1: 52% Latina, 48% non-Latina white G2: 26% Latina, 74% non-Latina white65 Other Role of CHW in Recruiting and Retention Unclear Recruitment Rates NA Retention Rates NA | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: NR Healthcare Utilization: Measure 1 comparison of mammography rates by intervention and ethnicity, via ICD codes on Medicaid claims (pre/post time-intervention interaction term by GEE) Results Latina, G1 vs. G2 adjusted GEE P = 0.07 Non-Latina, G1 vs. G2 adjusted GEE P = 0.10 Measure 2 Pre/post mammography rates via ICD codes on Medicaid claims Results Latina only analysis G1: 59 to 61% G2: 58% at baseline and followup, unadjusted rates not significant in either group, GEE model adjusting for insurance group, age, income, rural vs. urban, and disability found increased biennial mammograms in Intervention group (P = 0.03);64 Latina vs. white analysis G1: Latina 25→30% (unadjusted GEE P = 0.3); non-Latina 32→38% (unadjusted GEE P = 0.4) G2: Latina 45→43% (unadjusted GEE P = 0.27); non-Latina 41→44% (unadjusted GEE P = 0.02)65 | Costs (Economics): NR Explanation of Overall Outcomes CHW intervention in churches resulted in slight improvement in mammography rates among Medicaid-eligible Latinas, no statistically significant difference in ethnic disparities within promotora group, increased disparities in non promotora group (because non Latina had greater improvement than Latinas) Quality Rating Fair
Author Year Schuler et al., 2000 Trial Name NR Objective or Aim Effects of home-based intervention on mother-infant interaction among drug using women and their infants to compare mother–infant interaction among drug-using mothers who did and did not receive home-based intervention Geography Maryland NR Organization Organizational recruited from large university hospital Type of Community Drug abuse Inner city, African-American Study Design RCT Start Date NR Duration 6 months | Eligible (N) NR Enrolled (N) 192 families Randomized (N) 192 Completers (N) 171 Withdrawals or Dropouts (N) 21 families Not at all clear from article: “study included 171 families (87 control, 84 intervention). 31 dyads were lost before 2-week baseline visit, and 32 additional families lost after 2-week visit (see Table 1). Thus, 192 (97 control, 95 intervention) families seen for 6-month evaluation visit. Observation data dropped from 13 families because interaction involved caretaker other than mother, and data from 8 families were lost because of mechanical difficulties” Health Condition of Interest Infant health Maternal drug use; mother-child interaction Inclusion Criteria Women were eligible if they or their infants had a positive urine toxicology screen at birth or history of recent drug use was noted in medical charts. Exclusion Criteria Infants who were not discharged into care of their mothers or had serious developmental or congenital problems that required special services (e.g., spina bifida) Groups G1: CHW G2: Control Interventions G1: Visits to enhance mothers’ ability to manage self-identified problems by using existing services and family and social supports; modeling infant development behavior/activities G2: Meetings for tracking purposes only Group (N) G1: 84 G2: 87 | Title of CHW Lay Visitors Paid or Volunteer NR Relationship with Community Shared ethnicity African American women who “knew community” CHW (N) 3-2 for intervention, one for control group Supervision of CHW Visitors met with a psychologist and a pediatrician weekly to track progress of families and to discuss concerns about families Prior Training Past experience making home visits, no additional details provided Type of Service G1: home intervention was developmentally oriented and was based on program used by IHDP-visitors went once a week enhancing mothers’ ability to manage self-identified problems by using existing services and family and social supports; modelling infant development behavior/activities G2: brief monthly home tracking visits to reduce attrition Type of Educational Materials Used HELP at Home: Hawaii Early Learning Profile Duration of Interaction with Clients G1: 9 visits, about 30 minutes per visit G2: 3 visits, about 17 minutes each Length of Follow-up 6 months | Age (mean) 27 years Sex (% female) 100 Race (%) African American: 96% Other NR Role of CHW in Recruiting and Retention NR Recruitment Rates NR Retention Rates NR | Knowledge, Attitude, and Behavior: NR Quality of Life: Measure 1 Infant warmth measured by assessment of videotaped mother-infant interaction using previously validated scale Results No difference between groups. In control group, mothers who continued to use drugs were less responsive to their babies than were mothers who were drug free. In intervention group, drug use was not associated with maternal responsiveness. | Health Outcomes: Measure 3 Self-reported maternal drug use Results At 6 months, there were no significant group differences in cocaine and/or heroin use, alcohol use, or marijuana use during last 6 months Healthcare Utilization: NR | Costs (Economics): NR Explanation of Overall Outcomes No direct effects of intervention, in control group, mothers who continued to use drugs were less responsive to their babies than mothers who were drug free. In intervention group, drug use was not associated with maternal responsiveness. Quality Rating Fair
Author Year Schwarz et al., 1993 Trial Name Safe Block Project Objective or Aim Improve injury prevention knowledge and reduce number of hazards in home and reduce rates of injury occurring to residents of an inner city community. Geography Philadelphia Organization Social Type of Community Neighborhood High injury rate Study Design Prospective case-control observational Quasi-experimental; non-random controlled trial Start Date 1989 Duration 1 year 21 months | Eligible (N) 34 203 (17,058 intervention = approx 5,890 homes; 17,145 control) Enrolled (N) 2722 4476 (3004 received intervention, 1472 control homes randomly selected) Randomized (N) NA 2722 (1250 intervention + 1472 control homes selected for assessment) Completers (N) 1962 (902 intervention, 1060 control) Withdrawals or Dropouts (N) 28% not inspected in each group (348 intervention, 412 control) Health Condition of Interest Home Safety Inclusion Criteria Residents of 17 neighborhoods 9 census tracks with highest injury rates in community Exclusion Criteria NA inability to contact household residents Groups G1: Intervention G2: Control Interventions • Home modification for simple prevention measures • Home inspection to inform residents about hazards and ways of alleviating them • Education about selected injury prevention practices. Group (N) G1: 17 085 G2: 17 145 For postintervention assessments, 1250 of 3004 homes were randomly selected. assessments were conducted in 902 of1250 homes (72%). | Title of CHW Intervention team Paid or Volunteer Paid and volunteer Relationship with Community Shared community CHW (N) 3 community safety liaisons who recruited an undisclosed # of volunteer block supervisors and 10 safety inspectors. Supervision of CHW Supervised by personnel from Injury Control Section of Philadelphia Department of Public Health. Prior Training NR Type of Service Safety inspections home modifications, inspections, and education; myriad safety devices (e.g. smoke detectors, ipecac, emergency phone numbers, light bulbs, batteries, bathwater thermometer) Type of Educational Materials Used NR direct teaching from safety inspectors Duration of Interaction with Clients 1 home visit and monthly block meetings over 18 month-period (duration per session NR) Length of Follow-up 12 months | Age (mean) G1:< 5 yrs: 9.3%, 5–17 yrs: 17.6%, 18–64 yrs: 53.7%, >64 yrs: 19.5% G2:< 5 yrs: 9.9%, 5–17 yrs: 18.9%, 18–64 yrs: 58.1%, >64 yrs: 13.1% Sex (% female) NR Race (%) G1: African-American: 96.8%, Other: 3.2% G2: African-American: 95.7%, Other: 4.3% Other Injuries in 1987-rate per 1000 residents G1: 17.1 G2: 15.7 Role of CHW in Recruiting and Retention Block Representatives were asked to urge neighbors to participate in project. Recruitment Rates NR Retention Rates NR | Knowledge, Attitude, and Behavior: Measure 1 No syrup of ipecac for children< 5 yrs Results G1: 29% G2: 90.2% P< 0.001 Adjusted OR, 0.04 95% CI, 0.02–0.07 Measure 2 Inadequate light on stairs Results G1: 17.9% G2: 19.9% P = 0.41 Adjusted OR, .41 95% CI, 0.69–1.16 Measure 3 Hot water ≥125°F Results G1: 36.8% G2: 26.8% P< 0.001 Adjusted OR, 1.73 95% CI, 1.39, 2.15 Measure 1 No bedside light for >64 yrs adults Results G1: 13.3% G2: 15.1% P = 0.90 Adjusted OR, 1.03 95% CI, 0.68–1.57 Measure 2 No smoke detectors Results G1: 4% G2: 23% P< 0.001 Adjusted OR, 0.14 95% CI, 0.09– 0.20 Quality of Life: NR | Health Outcomes: NR Healthcare Utilization: NR | Costs (Economics): NR Explanation of Overall Outcomes Principal positive finding of this study is a distinct difference between control and intervention homes with respect to safety knowledge and home hazards that required minimal to moderate effort to correct. Intervention homes were found to be safer than control homes, particularly with respect to hazards related to fires and poisonings. Quality Rating Poor
Author Year Silver et al., 1997 Trial Name Parent to Parent Network Objective or Aim Evaluate psychological outcomes of Parent-To-Parent Network (PTPN), a community-based support program for mothers of five-to eight-year-old children with a variety of ongoing health conditions Geography NYC - Bronx; or Lower Westchester Organization Organizational Large urban medical centers; community-based delivery of intervention Type of Community Mothers that have children with chronic disease Inner-city, low- income, minority Study Design RCT Start Date 1990 Duration 1–2 years | Eligible (N) 512 Enrolled (N) 365 mothers Randomized (N) 365 Completers (N) 94% completed 12 month interview (343) Withdrawals or Dropouts (N) 6% LTF Health Condition of Interest Maternal health Mothers’ psychiatric well-being Inclusion Criteria • Five-to-eight-year-old children who had ongoing health conditions (defined as one that had lasted or was expected to last for at least three months or had required hospitalization for 30 days or more in previous year) • Mother could speak conversational english and live with her child in catchment area • Have easy access to a phone Exclusion Criteria A family was excluded if child was moderately or severely mentally retarded or had a life expectancy under 18 months. Groups G1: Experimental G2: Control Interventions G1: 6 one-hour meetings and 3 group activities 6 face-to-face interventions at home or in hospital + telephone calls + group activities G2: Usual care Group (N) G1: 183 G2: 182 | Title of CHW Lay Intervenor Paid or Volunteer NR (guessing paid) Paid (“accepted jobs”) Relationship with Community Shared experience Same neighborhoods (recruited via community newspapers); raised children with ongoing healht conditions CHW (N) 3 Supervision of CHW Supervised by a clinical psychologist and a social worker - frequency NR Prior Training 40 hours plus intensive training Type of Service Counselling, face-to-face meetings; telephone calls; group activities with others in program Type of Educational Materials Used NR Duration of Interaction with Clients 6 meetings (1 hour each) with at least biweekly telephone calls + 3 group social activities over 12 months Length of Follow-up 12 months 6, 12, and 18 mo | Age (mean) Mother’s age G1: 34.7 G2: 34.0 Children’s age G1: 7.2 G2: 7.0 Sex (% female) 100% female (mothers) Children G1: (45%) G2: (47%) Race (%) Mother’s ethnicity % Hispanic G1:43 G2: 46 Black G1: 41 G2:32 White, not Hispanic G1:11 G2: 17 Mixed/Other G1: 5 G2: 6 Other Asthma 35%, sickle cell anemia, epilepsy, and congenital heart disease (8% each), and cleft lip or palate, cancer, and endocrine disorders (5% each). Spina bifida and other congenital anomalies each occurred in 2%; 15% had multiple health conditions, mostly asthma G1: 35% fair to poor health; G2: 31% Role of CHW in Recruiting and Retention NR Recruitment Rates NR Retention Rates G1: 95% G2: 93% | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: Measure 1 PSI Results Pre- intervention G1: 24.1 G2: 20.3 (P< 0.05) Post intervention G1: 22.1 G2: 20.1 (no significant difference between groups) Measure 2 PSI subsets Results All adjusted posttest scores other than Depression were directionally lower in EG than CG Healthcare Utilization: NR | Costs (Economics): NR Explanation of Overall Outcomes Posttest scores of EG and CG mothers did not differ significantly. Although intervention effects were not related to participation level or illness-related and sociodemographic factors, a significant interaction with stressful life events (SLE) was found. Quality Rating Fair
Author Year St. James et al., 1999 Trial Name Resource Mothers Program for Maternal PKU Objective or Aim Increase number of well-treated pregnancies and thus reduce number of adverely affected offspring Geography New England Organization Maternal PKU Collaborative Study enrollees Type of Community PKU Study Design Retrospective cohort Start Date NR Duration NR | Eligible (N) NR Enrolled (N) 83 pregnancies from 69 mothers Randomized (N) NA Completers (N) NA Withdrawals or Dropouts (N) NA Health Condition of Interest PKU outcomes in children Inclusion Criteria Mothers with PKU Exclusion Criteria NA Groups G1: control (no resource mother) - women with PKU G2: PKU women with resource mother Interventions G1: NR G2: resource mothers met with pregnant women for approx 20 sessions of 2 hours each, weekly in beginning and less frequently as pregnancy proceeded. Activities included cooking, shopping, meal planning, preparing for baby, discussing pregnancy, discussing medical recommendations. Group (N) G1: 64 offspring from 55 mothers G2: 19 offspring from 14 mothers | Title of CHW Resource Mother Paid or Volunteer Paid Relationship with Community Resource mothers had children with PKU CHW (N) NR Supervision of CHW NR Prior Training Lived with disease Type of Service Face-to-face meetings Type of Educational Materials Used NR Duration of Interaction with Clients ≈20 sessions of 2 hours each (weekly in beginning then less frequently) throughout pregnancy Length of Follow-up 12 months after birth | Age (mean) Maternal age G1: 26.5 G2: 24.1 Sex (% female) 100 Race (%) NR Other Role of CHW in Recruiting and Retention NR Recruitment Rates NR Retention Rates NR | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: Measure 1 Birth head-circumference z score Results G1: −1.4 (95% CI, −1.56 – −1.2) G2: −0.56 (95% CI, −0.88 – −0.24); P = 0.08 Measure 2 Baylely developmental quotient Results G1: 95 (95% CI, 92–98) G2: 108 (95% CI, 104–112); P< 0.05 Measure 3 maternal metabolic control Results G1: 16.1 weeks(95% CI, 14.4–17.8) G2: 8.5 weeks (95% CI, 6.3–10.7); P< 0.05 Healthcare Utilization: NR | Costs (Economics): NR Explanation of Overall Outcomes NR Quality Rating Fair
Author Year Sung et al., 1997; Sung et al., 1992^71^ Trial Name National Black Women’s Health Project Objective or Aim Test effectiveness of in-home, culturally sensitive educational program conducted by lay health workers by measuring improvement in frequency of breast and cervical cancer screening Geography Unclear, possibly Atlanta Organization Inner city community health center Type of Community Inner city African-American Study Design RCT Start Date NR Duration 17 months | Eligible (N) NR Enrolled (N) 321 Randomized (N) 321 Completers (N) 195 Withdrawals or Dropouts (N) 126 Health Condition of Interest breast cancer, cervical cancer Inclusion Criteria NR Exclusion Criteria NR Groups G1: intervention G2: control Interventions G1: CHW home visits, education on breast and cervical cancer, breast self-exam, educational materials on screening, facilitation to address logistical barriers to screening G2: mailed educational materials on cancer screening Group (N) G1: 163 G2: 158 | Title of CHW Lay health worker Paid or Volunteer NR Relationship with Community Recruited from National Black Women’s Health Project CHW (N) NR Supervision of CHW NR Prior Training Self-help support group leaders within NBWHP Type of Service Home visits Type of Educational Materials Used Home visits, video of Pap and breast exam, printed materials Duration of Interaction with Clients 3 visits (months 1, 2, 4) over four month period, visits 1 and 2 1.5 hours each, time for visit 3 NR Length of Follow-up 11 months | Age (mean) G1: 18–34: 13.5% 35–44: 46% 45–59: 22.1% 60–97: 18.4% G2: 18–34: 13.3% 35–44: 44.3% 45–59: 24.7% 60–97: 17.7% Sex (% female) 100 Race (%) NR (presumed 100% African American) Other G1: Income ≤$15,000: 45.4% Married: 33.7% >HS education: 40.5% Employed: 55.2% G2: Income ≤$15,000: 48% Married: 30.4% >HS education: 38.4% Employed: 46.8% Role of CHW in Recruiting and Retention NR Recruitment Rates 1st attempt: 20% (55/275) 2nd attempt: 44% (266/600) Retention Rates G1: 57% (93/163) G2: 65% (102/158) | Knowledge, Attitude, and Behavior: Measure 1 Pretest-posttest change in self-report of BSE for entire sample Results G1: 52.1%/51.0%; G2: 41.1%/41.0%, diff in change: −1.0 (95% CI, −6.1–4.1) Measure 2 Pretest-posttest change in self-report of BSE, post-intervention respondents only Results G1: 57.0%/53.8%; G2: 40.2%/40.2%, diff in change: −3.2 (95% CI, −17.5, 11.1) Measure 3 Posttest report of BSE, women not previously on recommended screening schedules, whole sample Results G1: 24.4%; G2: 17.2%, diff in change: 7.2% (95% CI, −5.0–19.3) Measure 4 Posttest report of BSE, women not previously on recommended screening schedules, post-intervention respondents only Results G1: 47.5%; G2: 26.2%, diff in change: 21.3% (95% CI, 2.3–40.3) Quality of Life: NR | Health Outcomes: Measure 1 Pre/post change in self-report of receiving screening exams, women not previously on recommended screening schedules, whole sample Results No significant difference between groups for any screening modality Healthcare Utilization: Measure 1 Pretest-posttest change in self-report of receiving Pap smears for entire sample Results G1: 50.3%/58.7%; G2: 51.9%/62.1%, diff in change: −1.8 (95% CI, −8.0–4.4) Measure 2 Pretest-posttest change in self-report of receiving Pap smears, postintervention respondents only Results G1: 52.7%/63.4%; G2: 50.0%/62.7%, diff in change: −2.0 (95% CI, −11.0–7.0) Measure 3 Posttest rate of self-report of receiving Pap smears, women not previously on recommended screening schedules, whole sample Results G1: 33.3% G2: 34.2% diff in change: −0.9 (95% CI, −15.7–13.9) Measure 4 Posttest rate of self-report of receiving Pap smears, women not previously on recommended screening schedules, postintervention respondents only Results G1: 61.4% G2: 51.0% diff in change: 10.4 (95% CI, −9.5–30.0) Measure 5 Pretest-posttest change in self-report of receiving mammography for entire sample Results G1: 35.5%/50.4% G2: 34.3%/39.4% diff in change: 9.8% (95% CI, 2.9–16.7) Measure 6 Pretest-posttest change in self-report of receiving mammography, postintervention respondents only Results G1: 32.5%/58.7%; G2: 34.0%/47.9%, diff in change: 12.4% difference (95% CI, 1.0–24.3) Measure 7 Posttest rate of self-report of receiving mammography, women not previously on recommended screening schedules, whole sample Results G1: 29.7% G2: 24.4% diff in change: 5.8% (95% CI, −7.0–18.6) Measure 8 Posttest rate of self-report of receiving mammography, women not previously on recommended screening schedules, postintervention respondents only Results G1: 50.0% G2: 35.5% diff in change: 14.5% (95% CI, 4.5–23.6) Measure 9 Pretest-posttest change in self-report of receiving CBE for entire sample Results G1: 55.2%/64.5% G2: 55.7%/59.5% diff in change: 4.9 (95% CI, −6.1–4.1) Measure 10 Pretest-posttest change in self-report of receiving CBE, postintervention respondents only Results G1: 59.1%/72.0% G2: 57.8%/61.8% diff in change: 8.9% (95% CI, 1.1–16.7) Measure 11 Posttest rate of self-report of receiving CBE, women not previously on recommended screening schedules, whole sample Results G1: 37.0% G2: 28.6% diff in change: 8.4% (95% CI, -6.9-23.7) Measure 12 Posttest rate of self-report of receiving CBE, women not previously on recommended screening schedules, postintervention respondents only: Results G1: 71.1% G2: 46.5% diff in change: 24.6% (95% CI, 3.9-45.3) | Costs (Economics): NR Explanation of Overall Outcomes CHW intervention effective in increasing receipt of clinical breast exam and mammogram, only when including women already on some recommended screening schedule, and only when nonrespondents are assumed to be similar to respondents. Using intention-to-treat, no differences in any screening modality Quality Rating Poor
Author Year Taylor et al., 2002 Trial Name NR Objective or Aim Evaluate impact of 2 culturally and linguistically appropriate cervical cancer control educational interventions: a “high intensity” outreach worker- based intervention and a “low intensity” direct mail intervention Geography Seattle and Vancouver BC Organization Recruited from respondents to community-based survey Type of Community Chinese-American women Study Design RCT Start Date 1999 Duration 18 months | Eligible (N) 2312 (986 Seattle, 1326 Vancouver) (numbers deduced from text) Enrolled (N) 1532 (710 Seattle, 822 Vancouver) Randomized (N) 482 (199 Seattle, 283 Vancouver) Completers (N) 402 (181 Seattle, 221 Vancouver) Withdrawals or Dropouts (N) 80 (18 Seattle, 62 Vancouver) Health Condition of Interest Pap testing Inclusion Criteria •Chinese women •No history of Pap or intention of Pap within 2 years of survey •20-69 years old •Speak Cantonese, English, or Mandarin Exclusion Criteria •Hysterectomy •Invasive cervical cancer Groups G1: CHW G2: direct mail G3: control Interventions G1: Introductory mailing, CHW visit with multimedia and tailored counseling, phone followup and tailored counseling, logistic assistance as needed G2: Direct mail multimedia materials G3: Control: usual care at local clinics and doctors’ offices Group (N) G1: 161 G2: 161 G3: 160 | Title of CHW Outreach worker Paid or Volunteer NR Relationship with Community Shared culture, ethnicity CHW (N) NR Supervision of CHW NR Prior Training NR Type of Service Trained to act as role models, to provide social support, to serve as cultural mediators between women and health care facilities, to use visual aids and provide tailored responses to each woman’s individual barriers to cervical cancer screening Type of Educational Materials Used Video, motivational pamphlet, educational brochure, fact sheet, tailored counseling Duration of Interaction with Clients One time visit with follow up telephone call (time per interaction NR) Length of Follow-up 6 months | Age (mean) 58% 45-69 y/o: G1: 53% G2: 63% G3: 58% Sex (% female) 100 Race (%) Chinese 100% Other •12 or more years education: 44% •Married: 81% Role of CHW in Recruiting and Retention NR Recruitment Rates 66% (proportions not available for each group) Retention Rates 402/432 = 83% G1: 129/161 = 80% G2: 139/161 = 86% G3: 134/160 = 84% | Knowledge, Attitude, and Behavior: Measure 1 Report Pap testing planned within 2 years Results G1: 72% G2: 59% G3: 48% (G1 vs G3 P < 0.001 G2 vs G3: P = 0.05 G1 vs G2 P = 0.03) Quality of Life: NR | Health Outcomes: NR Healthcare Utilization: Measure 1 Medical records for pap screening received between randomization and followup, using intent-to-treat Results Results not provided, significant differences between outreach worker versus control (P < .001), direct mail versus control (P = .07), and outreach worker versus direct mail (P = .04) Measure 2 Medical records for pap screening received in past 2 years, using intent-to-treat Results Results not provided, significant differences between outreach worker versus control (P < .001) and direct mail versus control (P = .03) Measure 3 Self-reported Pap testing completed since intervention Results G1: 39% G2: 25% G3: 15% (G1 vs G3, P < 0.001 G2 vs G3, P = 0.03 G1 vs G2, P = 0.02) | Costs (Economics): NR Explanation of Overall Outcomes Women who received CHW home visits were significantly more likely to report having Pap testing after intervention compared to women receiving direct mail or no intervention Quality Rating Fair
Author Year Tessaro et al., 1997; Navaie- Waliser et al., 2000 Trial Name Maternal Outreach Worker (MOW) Program Objective or Aim Reduce infant morbidity and mortality via early prenatal care, consistence of care, health behavior and parenting skills, infant preventive care and social services, increased pregnancy spacing, decreasing unplanned pregnancies; to determine whether particip Geography North Carolina Organization Medicaid-eligible population, via social worker or nurse referral Type of Community High infant mortality with disproportionately higher in African-Americans vs. Caucasians Study Design prospective cohort Start Date 1992 Duration 3 years | Eligible (N) 14,977 Enrolled (N) 705 Randomized (N) NA Completers (N) 447 Withdrawals or Dropouts (N) 258 Health Condition of Interest Infant health Inclusion Criteria Medicaid-eligible, < 28 wk EGA, singleton livebirth; Caucasian or African-American (this study) Exclusion Criteria Moved away, lost to follow-up, declined services, interview not completed Groups G1: CHW G2: matched controls Interventions G1: CHW home visits Group (N) G1: 373 (yr 2) -- > 221 (yr 3) G2: 332 (yr 2) -- > 198 (yr 3) | Title of CHW Maternal Outreach Worker (MOW) Paid or Volunteer NR Relationship with Community NR CHW (N) NR Supervision of CHW NR Prior Training NR Type of Service Home visits, assistance in applying for govt benefits, housing, employment, education; general advocacy for families Type of Educational Materials Used Reinforcing positive health behavior; modeling parent-infant interactions; reinforce need for prenatal care, immunizations, family planning Duration of Interaction with Clients One visit/month (more if needed) for approximately 14 months (duration per visit NR) Length of Follow-up 1 year | Age (mean) < 18 y G1: 31% G2: 15.6% Sex (% female) 100 Race (%) G1: African-American: 61.8% Caucasian: 38.2% G2: African-American, 59.4% Caucasian (limited to African-American and Caucasian): 40.6% Other Often receive aid from friends/family G1: 41.4% G2: 58.1% (P < 0.001) Reported good health G1: 78.4% G2: 85.5% (P < 0.05) Social supportiveness of pregnancy G1: 52.6% G2: 62.9% (P < 0.05) Prior physical abuse by partner G1: 14.9% G2: 10% (P < 0.1) No difference in education, gravidity, smoking Role of CHW in Recruiting and Retention Active recruitment of very high risk population Recruitment Rates NR Retention Rates G1: 249/373 = 67% G2: 198/332 = 60% | Knowledge, Attitude, and Behavior: NR Quality of Life: NR | Health Outcomes: Measure 1 Low birth weight (observed minus expected) Results African-American: LBW -13 (P = 0.12); VLBW -6 (P = 0.1) Caucasian: LBW +1 (P = 0.58); VLBW 0 (P = 0.6) Measure 2 Prenatal care adequate (Kessner index) Results African American G1: Adequate: 60.7% Intermediate: 32.6% Inadequate: 6.7% G2: Adequate: 63.8% Intermediate: 31.5% Inadequate: 4.7% Caucasian: G1: Adequate: 77.4% Intermediate: 19.7% Inadequate: 2.9% G2: Adequate: 75.1% Intermediate: 22.8% Inadequate: 2.1% Healthcare Utilization: NR | Costs (Economics): NR Explanation of Overall Outcomes CHW visits resulted in higher proportion of adequate care for Caucasian but lower for African-Americans (significant difference for African-Americans); fewer than expected LBW and VLBW for African-Americans but not Caucasians Quality Rating Poor
Author Year Von Korff et al., 1998 Trial Name NR Objective or Aim Evaluate a4- session self- management group intervention for patients with pain in primary care, led by trained lay persons with back pain. intervention was designed to reduce patient worries, encourage self-care, and reduce activity limitations. Geography Western Washington State Organization HMO Type of Community Condition - back pain Study Design RCT Start Date 1996 Duration NR | Eligible (N) 364 Enrolled (N) 255 Randomized (N) 255 Completers (N) 0.85 Withdrawals or Dropouts (N) 0.145 Health Condition of Interest Back pain Inclusion Criteria Patients diagnosed with back pain ages 25-70, at least one prior back pain visit, interested in learning more about caring for back pain, enrolled for at least a year Group Health Cooperative of Puget Sound Exclusion Criteria Surgery or disenrollment from GHC Groups G1: Self management group G2: Usual care Interventions G1: Four 2-hour classes held once a week, with 10 to 15 participants, led by two trained volunteers. G2: Usual care includes back pain book Group (N) G1: 129 G2: 126 | Title of CHW Lay leaders Paid or Volunteer Volunteer Relationship with Community Shared disease CHW (N) 8 Supervision of CHW NR Prior Training NR Type of Service classes Type of Educational Materials Used Book, pamphlets, videotapes Duration of Interaction with Clients Four 2-hour classes held once a week for 1 month Length of Follow-up 12 months | Age (mean) G1: 49.4 G2: 50.3 Sex (% female) G1: 68.2 G2: 56.4 Race (%) G1: White: 91.4% Non-white: 8.6% G2: White: 79.7% Non-white: 20.3% Other Role of CHW in Recruiting and Retention NR Recruitment Rates NR Retention Rates NR | Knowledge, Attitude, and Behavior: Measure 1 “Next time I have back or leg pain, I will try to manage problem without seeing a health professional” - Not validated Results G1: 77% agreed G2: 60% (P = 0.008) Quality of Life: NR | Health Outcomes: Measure 1 Roland Disability at 12 months - validated Results G1: 5.75 (6.31) G2: 6.75 (6.39) P = 0.092 Measure 2 Worry rating (0-10) at 12 months - not validated Results G1: 2.63 (2.58) G2: 3.83 (3.08) P = 0.013 Measure 3 50% or greater reduction in Roland Disability Questionnaire Score from baseline at 6 months - validated Results G1: 47.9% G2: 33% (X2 = 5.2; df = 1; P = 0.02) Healthcare Utilization: NR | Costs (Economics): NR Explanation of Overall Outcomes NR Quality Rating Fair
Author Year Wendell et al., 2003 Trial Name NA Objective or Aim To determine whether street outreach to prevent HIV infection as practised by state-funded community-based organizations (CBOs) is effective in promoting condom use Geography Louisiana Organization Neighborhoods through out state characterized by one or more of following: high rates of STD/HIV, high levels of drug use, exchange of sex for money or drugs, ‘crack’ houses, or injection drug users Type of Community At risk neighborhoods Study Design Observational - cross sectional Start Date 1998 Duration 2 years | Eligible (N) NA Enrolled (N) NA Randomized (N) NA Completers (N) NA Withdrawals or Dropouts (N) NA Health Condition of Interest HIV prevention Inclusion Criteria NA Exclusion Criteria NA Groups G1: Intervention G2: Comparison Interventions G1: Discussions with community members during which they assessed client’s needs, imparted a risk- or harm-reduction message on sexual disease, answered questions, made referrals, and negotiated and reinforced behaviour change. Group (N) G1: 4950 G2: 1597 | Title of CHW Outreach workers Paid or Volunteer Paid Relationship with Community Members of community except in New Orleans CHW (N) at least 42 Supervision of CHW OPH (Office of public health) Prior Training NR Type of Service Interview - survey interaction Type of Educational Materials Used Condoms, educational materials, bleach kits, coupons for new needles, services such as substance abuse treatment, STD care and social services Duration of Interaction with Clients Brief - Most interactions involved introducing themselves, handing out condoms and literature and perhaps delivering a brief prevention message Length of Follow-up NA | Age (mean) G1: 12-14 yrs: 2% 15-19 yrs: 27% 20-24 yrs: 24% 25-34 yrs: 27% 35+ yrs: 20% G2: 12-14 yrs: 1% 15-19 yrs: 24% 20-24 yrs: 23% 25-34 yrs: 28% 35+ yrs: 24% Sex (% female) G1: 48 G2: 40 Race (%) G1: African American: 89% White: 7% Other: 4% G2: African American: 87% White: 8% Other :5% Other Two or more sexual partners G1: 72 69 G2:1.14 OR 95% CI (1.01, 1.29) P = 0.04 Men who had sex with men (men only) G1: 16 11 G2: 1.64 OR 95% CI, (1.3, 2.06) P = 0.001 Injected drugs G1: 7% G2: 4% OR 95% CI, 1.8 (1.37, 2.37) P = 0.001 Role of CHW in Recruiting and Retention NA Recruitment Rates NA Retention Rates NA | Knowledge, Attitude, and Behavior: Measure 1 Survey - not validated Results Know where to get free condoms G1: 90 G2: 74 OR 95% CI, 3.2 (2.75, 3.73) P = 0.001 Quality of Life: NR | Health Outcomes: Measure 1 Survey - not validated Results Condom use Intervention vs. comparison [odds ratio 1.37 (95% confidence Interval 1.20, 1.56; P<0.001)]. Healthcare Utilization: NR | Costs (Economics): NR Explanation of Overall Outcomes NR Quality Rating Fair
Author Year Wilson et al., 2008 Trial Name NR Objective or Aim Assess effectiveness of breast health promoting messages administered by salon stylists to clients in salon setting Geography Brooklyn, NY Organization Neighborhood hair salons Type of Community Neighborhoods Study Design Repeated cross- sectional survey of women attending salons randomly assigned to experimental and control groups Start Date 2002 Duration 3 months for each salon | Eligible (N) 257 salons Enrolled (N) NR Randomized (N) 40 salons Completers (N) 40 salons/1210 respondents Withdrawals or Dropouts (N) NA Health Condition of Interest breast cancer Inclusion Criteria Salons providing services in target NYC neighborhoods; clients receiving services at experimental and control salons were eligible to participate Exclusion Criteria Salons were excluded if owner was a member of Health and Beauty Council Groups G1: Control salon, at baseline G2: Experimental salon, at baseline G3: Control salon, at followup G4: Experimental salon, at followup Interventions G1: Control, before intervention G2: Stylists group, before intervention G3: Control, after intervention G4: Stylists group, after intervention Intervention consisted of education, counseling, and information on location of screening services during salon appointment Group (N) G1: 369 (12 salons) G2: 816 (28 salons) G3+G4: 1210 (N of salons NR, individual N NR) | Title of CHW Lay health advisor Paid or Volunteer Volunteer (with $30 compensation for training time) Relationship with Community Hair stylist working in neighborhood/community CHW (N) 29 Supervision of CHW Program staff made frequent visits to salons to support stylists in their promotion of message delivery throughout time during which program was administered. Prior Training NR Type of Service One-on-one counseling during salon visit to provide education, counseling, and information on location of cancer screening services Type of Educational Materials Used Written materials (not described) Duration of Interaction with Clients One visit - (time of session NR) Length of Follow-up 3 months | Age (mean) G1: 38 G2: 39 G3+G4: 38 Sex (% female) 100 Race (%) African G1: 91 G2: 93 Hispanic G1: 7 G2: 6 Other G1: 2 G2: 1 Other Born in US (%) G1: 56 G2: 52 Family hx of breast cancer (%) G1: 10 G2: 9 Role of CHW in Recruiting and Retention NA Recruitment Rates NA Retention Rates NA | Knowledge, Attitude, and Behavior: Measure 1 Engaging in BSE in past 3 months Results G1: 25% G2: 28%, P = 0.26 for differences between G1 and G2 G3: 37% G4: 40% Adjusted OR, for differences between G3: and G4 1.3; Adj 95% CI, 0.9–1.7 Measure 2 Intention to receive mammogram in next year Results G3: 70% G4: 74% Adj OR 1.3; Adj 95% CI, 0.9–1.2 Quality of Life: NR | Health Outcomes: NR Healthcare Utilization:<br>Measure 1 Clinical breast exam (CBE) in past 3 months Results G1: 27% G2: 27%, P = 0.85 for differences between G1 and G2 G3: 27% G4: 29% AOR 1.2 (95% CI, 0.9–1.7) Measure 2 Mammogram in past 3 months Results G1: 13% G2: 14% Adj OR 1.1; Adj 95% CI, 0.8–1.7 | Costs (Economics): NR Explanation of Overall Outcomes NR Quality Rating Poor
Author Year Wolff et al. 1997; Morse et al. 1997 Trial Name NR Objective or Aim Three types of case management were compared to determine their relative effectiveness in helping people with severe mental illness who were homeless or at risk of homelessness. and cost- effectiveness of three approaches to case management for individuals with severe mental illness who were at risk for homelessness Geography St. Louis, Missouri Organization Organizational Type of Community Mental Illness and homelessness Study Design RCT Start Date 1990 Duration 18 months | Eligible (N) 204 Enrolled (N) NR Randomized (N) 165 Completers (N) 135 (Outcomes based on 85) Withdrawals or Dropouts (N) 30 Health Condition of Interest Mental illness Inclusion Criteria Current homelessness or risk for homelessness; serious DSM-III-R axis I diagnosis; no recent convictions for rape, homicide, or serious assault; and willingness to receive services and participate in a longitudinal study Exclusion Criteria See Inclusion criteria Groups G1: Assertive community treatment G2: Assertive community treatment with community workers, G3: Receiving brokered case management (purchase of services). Interventions G1: Assertive community treatment - intensive individualized treatment, responsibility for providing or coordingating all services needed by client, persistent follow-up and in vivo service delivery, performed by staff with backgounds in psychology, social work, and counseling G2: G1 + Community Health Worker, whose role was to assist with activities of daily living and be available for leisure activities Group (N) NR for primary intervention study G1: 28 in assertive community treatment G2: 35 in assertive community treatment with community workers, G3: 22 receiving brokered case management (purchase of services). | Title of CHW Community worker Paid or Volunteer Some paid and some volunteer Relationship with Community NR CHW (N) NR Supervision of CHW NR Prior Training NR Type of Service Included participation in individual and community leisure activities. Some also supplemented work of assertive community treatment staff by assisting clients with activities of daily living, although this usually occurred only on a limited basis. Type of Educational Materials Used NR Duration of Interaction with Clients Face-to-face meetings (length of each and number NR) over 18 months Length of Follow-up 18 months | Age (mean) 33.6 years Sex (% female) 41.2 Race (%) • African-American: 55.3 % • Aglo-American: 44.7% Other Role of CHW in Recruiting and Retention NR Recruitment Rates NR Retention Rates NR | Knowledge, Attitude, and Behavior: NR Quality of Life: Measure 1 Client Satisfaction Results G1: 3.27(0.42) G2: 3.12(0.57) G3: 2.74(0.68) P < 0.01 Measure 2 N of days in stable housing in past month Results Basline(SD)/18 months(SD) G1: 6.36(11.71)/21.75(12.76) G2: 4.94(11.08)/17.54(14.45) G3: 7.18(12.38)/16.00(14.86) (P < 0.31) | Health Outcomes: Measure 1 BPRS (Brief Psychiatric Rating Scale score) Total Symptom Score Results G1:53.54(15.54)/39.96(12.25) G2: 57.97(20.29)/38.77(12.23) G3: 50.6(14/31)/51.6(16.7) P = 0.001 Healthcare Utilization: Measure 1 Program contact (days/mo) Results G1:8.29(7.51) G2: 6.95(4.91) G3: 0.3(0.49) P < 0.001 | Costs (Economics): Measure 1 Total costs over 18- month study period for average client in each treatment condition Results Assertive community treatment only, $49,510; No significant difference Assertive community treatment with community workers, $39,913; brokered case management, $45,076 Explanation of Overall Outcomes NR Quality Rating Poor

Evidence Table C-2 Key Questions 1, 2, and 3: Quality RCTs

Study Characteristics Background Inclusion/Exclusion Criteria Randomization Interventions/Exposure Contamination Blinding | Soundness of Information Follow-Up Analysis Comparability/Outcome
Author Year Andersen et al., 2000 Hypothesis/Aim/ Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized Yes Allocation of Randomization Adequately Concealed? NR Level of Detail in Describing Intervention/Exposure Medium Usual Clinical Care Described? No Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? No Could Variation from Protocol have Compromised Study Findings? Cannot determine Outcome Assessors Masked? No Care Provider Masked? No Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? NR Outcomes Measured in Valid and Reliable Manner Retrospective self-report Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? No Did Attrition Differ by More Than 15 Percentage Points After Randomization? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? Yes Does Analysis Control for Baseline Differences? Yes Analysis Conducted on ITT Basis? Yes Any Post-Randomization Exclusions? Cannot tell Conclusions Supported by Results? Yes Quality Rating Good
Author Year Auslander, et al., 2002; Williams et al., 2001 Hypothesis/Aim/ Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized NR Allocation of Randomization Adequately Concealed? NR Level of Detail in Describing Intervention/Exposure Medium Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? No Could Variation from Protocol have Compromised Study Findings? No Outcome Assessors Masked? NR Care Provider Masked? No Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? Retrospective self-report (patient/participant response) Outcomes Measured in Valid and Reliable Manner Retrospective self-report (patient/participant response) Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? Cannot determine Did Attrition Differ by More Than 15 Percentage Points After Randomization? Cannot determine Baseline Characteristics Similar in Exposed/Comparison Cohorts? Yes Does Analysis Control for Baseline Differences? NA Analysis Conducted on ITT Basis? No Any Post-Randomization Exclusions? Cannot tell Conclusions Supported by Results? Partially Quality Rating Fair
Author Year Barnes et al., 1999 Hypothesis/Aim/ Objective of Study Described? Yes Criteria Clearly Stated? Partially Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized Yes Allocation of Randomization Adequately Concealed? NR Level of Detail in Describing Intervention/Exposure Medium Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? No Could Variation from Protocol have Compromised Study Findings? Cannot determine Outcome Assessors Masked? Not reported Care Provider Masked? No Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? Prospective documentation Outcomes Measured in Valid and Reliable Manner Objective Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? Yes: 24% in G1 Did Attrition Differ by More Than 15 Percentage Points After Randomization? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? No Does Analysis Control for Baseline Differences? No Analysis Conducted on ITT Basis? No Any Post-Randomization Exclusions? Yes many as they were randomized before enrollment Conclusions Supported by Results? Partially Quality Rating Fair
Author Year Barth, 1991 Hypothesis/Aim/ Objective of Study Described? YES- kind of Criteria Clearly Stated? Partially Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized No Allocation of Randomization Adequately Concealed? Can't tell so No Level of Detail in Describing Intervention/Exposure Low Usual Clinical Care Described? No Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? No Could Variation from Protocol have Compromised Study Findings? Cannot determine Outcome Assessors Masked? No Care Provider Masked? NA Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? Objective in some Outcomes Measured in Valid and Reliable Manner Objective in some Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? No Did Attrition from Any Group Exceed 20% After Randomization? Yes Did Attrition Differ by More Than 15 Percentage Points After Randomization? Yes Baseline Characteristics Similar in Exposed/Comparison Cohorts? Yes Does Analysis Control for Baseline Differences? Yes Analysis Conducted on ITT Basis? No Any Post-Randomization Exclusions? Yes at least 3 Conclusions Supported by Results? Partially Quality Rating Poor
Author Year Barth et al., 1988 Hypothesis/Aim/ Objective of Study Described? YES- kind of Criteria Clearly Stated? Partially Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized No Allocation of Randomization Adequately Concealed? Can't tell so No Level of Detail in Describing Intervention/Exposure Low Usual Clinical Care Described? No Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? No Could Variation from Protocol have Compromised Study Findings? Cannot determine Outcome Assessors Masked? Not reported Care Provider Masked? NA Patient Masked? Not reported | Interventions/Exposures Measured in Valid and Reliable Manner? Objective in some Outcomes Measured in Valid and Reliable Manner Objective in some Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? No Did Attrition from Any Group Exceed 20% After Randomization? Yes Did Attrition Differ by More Than 15 Percentage Points After Randomization? Yes Baseline Characteristics Similar in Exposed/Comparison Cohorts? Yes Does Analysis Control for Baseline Differences? Yes Analysis Conducted on ITT Basis? No Any Post-Randomization Exclusions? Yes at least 3 Conclusions Supported by Results? Partially Quality Rating Poor
Author Year Batts et al., 2001; Gary et al., 2005; Gary et al., 2003; Gary et al., 2000; Vetter et al., 2004 Hypothesis/Aim/ Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No (and primary outcome not clearly identified) Assignment Randomized Yes Allocation of Randomization Adequately Concealed? NR Level of Detail in Describing Intervention/Exposure Medium Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? Yes Could Variation from Protocol have Compromised Study Findings? Yes Outcome Assessors Masked? Yes Care Provider Masked? No Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? Objective measure, not validated Outcomes Measured in Valid and Reliable Manner Objective Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? No Did Attrition Differ by More Than 15 Percentage Points After Randomization? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? Yes Does Analysis Control for Baseline Differences? NA Analysis Conducted on ITT Basis? No (completers analysis) Any Post-Randomization Exclusions? No Conclusions Supported by Results? Yes Quality Rating Good
Author Year Becker et al., 2005; Cene et al., 2008 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized Yes Allocation of Randomization Adequately Concealed? NR Level of Detail in Describing Intervention/Exposure Low Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? Yes Could Variation from Protocol have Compromised Study Findings? Yes Outcome Assessors Masked? NR Care Provider Masked? NR Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? NR Outcomes Measured in Valid and Reliable Manner Retrospective self-report (patient/participant response) Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? Yes - G1:26% G2:27% Did Attrition Differ by More Than 15 Percentage Points After Randomization? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? No Does Analysis Control for Baseline Differences? NA Analysis Conducted on ITT Basis? Yes Any Post-Randomization Exclusions? No Conclusions Supported by Results? Yes Quality Rating Fair
Author Year Black et al., 1995; Hutcheson et al., 1997 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized Yes Allocation of Randomization Adequately Concealed? NR Level of Detail in Describing Intervention/Exposure Medium Usual Clinical Care Described? No Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? No Could Variation from Protocol have Compromised Study Findings? Cannot determine Outcome Assessors Masked? Yes Care Provider Masked? No Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? NR Outcomes Measured in Valid and Reliable Manner Objective, validated; and retrospective self-report Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? No Did Attrition Differ by More Than 15 Percentage Points After Randomization? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? Yes, for characteristics in table 1, but trend toward lower baseline receptive language in intervention group at baseline (table 2); no reporting of maternal baseline psychiatric measures Does Analysis Control for Baseline Differences? NA Analysis Conducted on ITT Basis? Yes Any Post-Randomization Exclusions? Cannot tell Conclusions Supported by Results? Partially (difficult to tell since there is no sample size calculation, no definition of primary outcome, numerous comparisons/outcomes evaluated, no clarity of what represents a clinically important difference for outcomes rather than just a statistically important difference, and there were baseline differences in receptive language socres...) Quality Rating Fair
Author Year Campbell et al., 2004 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? No Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized No Allocation of Randomization Adequately Concealed? No Level of Detail in Describing Intervention/Exposure Medium Usual Clinical Care Described? NA Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? No Could Variation from Protocol have Compromised Study Findings? No Outcome Assessors Masked? No Care Provider Masked? No Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? NR Outcomes Measured in Valid and Reliable Manner NR Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? Cannot determine Did Attrition Differ by More Than 15 Percentage Points After Randomization? Cannot determine Baseline Characteristics Similar in Exposed/Comparison Cohorts? No Does Analysis Control for Baseline Differences? Yes Analysis Conducted on ITT Basis? No Any Post-Randomization Exclusions? Cannot tell Conclusions Supported by Results? Partially Quality Rating Poor
Author Year Caulfield et al., 1998 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized No Allocation of Randomization Adequately Concealed? NA Level of Detail in Describing Intervention/Exposure Medium Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? Yes Could Variation from Protocol have Compromised Study Findings? Yes Outcome Assessors Masked? No Care Provider Masked? No Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? Retrospective self-report (patient/participant response) Outcomes Measured in Valid and Reliable Manner Retrospective self-report (patient/participant response) Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? 56% overall drop out Did Attrition Differ by More Than 15 Percentage Points After Randomization? NR Baseline Characteristics Similar in Exposed/Comparison Cohorts? No Does Analysis Control for Baseline Differences? Yes (via logistic regression) Analysis Conducted on ITT Basis? No Any Post-Randomization Exclusions? Yes Conclusions Supported by Results? Partially Quality Rating Poor
Author Year Conway et al., 2004 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? Yes Assignment Randomized NR (randomization method NR) Allocation of Randomization Adequately Concealed? NR Level of Detail in Describing Intervention/Exposure Low, broad concepts provided without detailed description of promotoras intervetion techniques Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? NA Could Variation from Protocol have Compromised Study Findings? NA Outcome Assessors Masked? Yes Care Provider Masked? No Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? Objective, not validated Outcomes Measured in Valid and Reliable Manner Objective, validated Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? No Did Attrition Differ by More Than 15 Percentage Points After Randomization? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? NR, no table 1, inadequate description of comparability of groups Does Analysis Control for Baseline Differences? NA Analysis Conducted on ITT Basis? No, completers analysis Any Post-Randomization Exclusions? Yes Conclusions Supported by Results? Yes Quality Rating Good
Author Year Corkery et al., 1997 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized NR Allocation of Randomization Adequately Concealed? NR Level of Detail in Describing Intervention/Exposure Medium Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? No Could Variation from Protocol have Compromised Study Findings? Cannot determine Outcome Assessors Masked? Not reported Care Provider Masked? Not reported Patient Masked? Not reported | Interventions/Exposures Measured in Valid and Reliable Manner? Objective (some validated, some not) and retrospective self-report Outcomes Measured in Valid and Reliable Manner Objective (some validated, some not) and retrospective self-report Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? Yes - 37% Did Attrition Differ by More Than 15 Percentage Points After Randomization? Yes Baseline Characteristics Similar in Exposed/Comparison Cohorts? Yes Does Analysis Control for Baseline Differences? No Analysis Conducted on ITT Basis? No Any Post-Randomization Exclusions? Cannot tell Conclusions Supported by Results? Partially Quality Rating Fair
Author Year Dean et al., 2000; Derose et al., 2000; Derose et al., 2000; Fox et al., 1998; Stockdale et al., 2000 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized NR Allocation of Randomization Adequately Concealed? NR Level of Detail in Describing Intervention/Exposure Medium Usual Clinical Care Described? No Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? Yes Could Variation from Protocol have Compromised Study Findings? No Outcome Assessors Masked? No Care Provider Masked? NA Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? Prospective documentation Outcomes Measured in Valid and Reliable Manner Retrospective self-report Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? Yes - 73% Did Attrition Differ by More Than 15 Percentage Points After Randomization? CD Baseline Characteristics Similar in Exposed/Comparison Cohorts? Yes Does Analysis Control for Baseline Differences? Yes Analysis Conducted on ITT Basis? CD Any Post-Randomization Exclusions? No Conclusions Supported by Results? Yes Quality Rating Fair
Author Year Dignan et al., 2005 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Partially Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized NR Allocation of Randomization Adequately Concealed? NR Level of Detail in Describing Intervention/Exposure Low Usual Clinical Care Described? No Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? No Could Variation from Protocol have Compromised Study Findings? Yes Outcome Assessors Masked? No Care Provider Masked? No Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? Prospective documentation Outcomes Measured in Valid and Reliable Manner Retrospective self-report Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? No (outcome asks about past 12 months, followup data obtained within 6 months) Did Attrition from Any Group Exceed 20% After Randomization? Yes - 29% Did Attrition Differ by More Than 15 Percentage Points After Randomization? Cannot determine Baseline Characteristics Similar in Exposed/Comparison Cohorts? Greater number of patients age 65+ in telephone group Does Analysis Control for Baseline Differences? Cannot determine Analysis Conducted on ITT Basis? Yes Any Post-Randomization Exclusions? Cannot tell Conclusions Supported by Results? Partially Quality Rating Poor
Author Year Duggan et al., 1999; Duggan et al., 2000 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Partially Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized No Allocation of Randomization Adequately Concealed? NA Level of Detail in Describing Intervention/Exposure Low Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? No Could Variation from Protocol have Compromised Study Findings? Yes Outcome Assessors Masked? No Care Provider Masked? No Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? Retrospective self-report (patient/participant response) Outcomes Measured in Valid and Reliable Manner Retrospective self-report (patient/participant response) Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? No Did Attrition from Any Group Exceed 20% After Randomization? No Did Attrition Differ by More Than 15 Percentage Points After Randomization? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? Yes Does Analysis Control for Baseline Differences? NA Analysis Conducted on ITT Basis? Yes Any Post-Randomization Exclusions? No Conclusions Supported by Results? Partially Quality Rating Poor
Author Year Elder et al., 2006; Elder et al., 2005 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized Yes Allocation of Randomization Adequately Concealed? NR Level of Detail in Describing Intervention/Exposure Low, many details about tailored print materials not provided (just general topics covered are identified); minimal description of what promotoras acually did Usual Clinical Care Described? NA Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? No Could Variation from Protocol have Compromised Study Findings? Cannot determine, possible there could be contamination if subjects in various groups had interactions w/each other Outcome Assessors Masked? No Care Provider Masked? No Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? NR Outcomes Measured in Valid and Reliable Manner Retrospective self-report (24-hour dietary recall) for primary outcomes; accuracy of measure is debatable given recall issues, social desirability/those working with promotoras may have greater desire to report lower intake of fat/etc. to please promotoras with which they've established a relationship. Of not, BMI changes from baseline were similar in all groups but decreased least in promotoras group—suggesting that intermediate measures used (dietary intake of fat, etc.) were not in line with BMI changes that would be expected. Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? No for 12 week outcomes; Yes for 1 year outcomes (G1 22%, G2 24%) Did Attrition Differ by More Than 15 Percentage Points After Randomization? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? No, important differences in perceived barriers to fat, stages of change for fat, …More participants in tailored condition (than promotoras group) were in earlier stages of change. Also, tailored group had worse overall health (per self-report) Does Analysis Control for Baseline Differences? No Analysis Conducted on ITT Basis? No Any Post-Randomization Exclusions? No Conclusions Supported by Results? Partially Quality Rating Poor
Author Year Gielen et al., 2002 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? Yes Assignment Randomized Yes Allocation of Randomization Adequately Concealed? Yes Level of Detail in Describing Intervention/Exposure Low Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? Yes Could Variation from Protocol have Compromised Study Findings? CD Outcome Assessors Masked? NR Care Provider Masked? No Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? Objective measure, not validated Outcomes Measured in Valid and Reliable Manner Objective meansure, not validated Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? Yes - 27% in standard; 15% in enhanced Did Attrition Differ by More Than 15 Percentage Points After Randomization? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? Yes Does Analysis Control for Baseline Differences? Yes Analysis Conducted on ITT Basis? CD Any Post-Randomization Exclusions? No Conclusions Supported by Results? Yes Quality Rating Fair
Author Year Graham et al., 1992 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? Yes Assignment Randomized Yes Allocation of Randomization Adequately Concealed? Yes Level of Detail in Describing Intervention/Exposure Medium Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? Yes Could Variation from Protocol have Compromised Study Findings? Cannot determine Outcome Assessors Masked? Yes Care Provider Masked? No Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? NR Outcomes Measured in Valid and Reliable Manner Objective Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? G1: 60% completers; 72% overall received some visits Did Attrition Differ by More Than 15 Percentage Points After Randomization? Yes (control group 100% of sample available) Baseline Characteristics Similar in Exposed/Comparison Cohorts? Cannot determine Does Analysis Control for Baseline Differences? NA Analysis Conducted on ITT Basis? Yes Any Post-Randomization Exclusions? Yes (24) Conclusions Supported by Results? Yes Quality Rating Fair
Author Year Hiatt et al., 2008 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? No Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized 2x2 Allocation of Randomization Adequately Concealed? No Level of Detail in Describing Intervention/Exposure Low Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? No Could Variation from Protocol have Compromised Study Findings? Yes Outcome Assessors Masked? No Care Provider Masked? No Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? Retrospective self-report Outcomes Measured in Valid and Reliable Manner Objective, previously validated Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? Yes Did Attrition Differ by More Than 15 Percentage Points After Randomization? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? No Does Analysis Control for Baseline Differences? Yes - some Analysis Conducted on ITT Basis? No Any Post-Randomization Exclusions? Cannot tell Conclusions Supported by Results? Yes Quality Rating Fair
Author Year Hunter et al., 2004 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized NR Allocation of Randomization Adequately Concealed? NR Level of Detail in Describing Intervention/Exposure Medium Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? Yes Could Variation from Protocol have Compromised Study Findings? No Outcome Assessors Masked? NR Care Provider Masked? NR Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? Objective measure, not validated Outcomes Measured in Valid and Reliable Manner Objective Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? No Did Attrition Differ by More Than 15 Percentage Points After Randomization? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? Yes Does Analysis Control for Baseline Differences? NA Analysis Conducted on ITT Basis? Yes Any Post-Randomization Exclusions? No Conclusions Supported by Results? Yes Quality Rating Fair
Author Year Jandorf et al., 2005 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized Yes Allocation of Randomization Adequately Concealed? No Level of Detail in Describing Intervention/Exposure Medium Usual Clinical Care Described? No Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? No Could Variation from Protocol have Compromised Study Findings? Cannot determine Outcome Assessors Masked? No Care Provider Masked? Yes Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? Objective Outcomes Measured in Valid and Reliable Manner Objective Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? No Did Attrition Differ by More Than 15 Percentage Points After Randomization? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? Yes Does Analysis Control for Baseline Differences? NA Analysis Conducted on ITT Basis? Yes Any Post-Randomization Exclusions? No Conclusions Supported by Results? Yes Quality Rating Fair
Author Year Korfmacher et al., 1999; Olds et al., 2002; Olds et al., 2004 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? Yes Assignment Randomized Yes Allocation of Randomization Adequately Concealed? Yes Level of Detail in Describing Intervention/Exposure Medium Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? Yes Could Variation from Protocol have Compromised Study Findings? Cannot determine Outcome Assessors Masked? Yes Care Provider Masked? No Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? Prospective documentation Outcomes Measured in Valid and Reliable Manner Objective, some validated; Prospective documentation Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? Yes - G1 48%, G2 38% Did Attrition Differ by More Than 15 Percentage Points After Randomization? Yes - G1 48%, G2 38%, G3 20% Baseline Characteristics Similar in Exposed/Comparison Cohorts? Yes Does Analysis Control for Baseline Differences? NA Analysis Conducted on ITT Basis? Yes Any Post-Randomization Exclusions? Yes (G1 = 11, G2 = 12, G3 = 17 in one study); Yes (G1 = 34, G2 = 35, G3 = 34 in another study) Conclusions Supported by Results? Yes Quality Rating Fair
Author Year Krieger et al., 1999 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? Yes Assignment Randomized Yes Allocation of Randomization Adequately Concealed? Yes Level of Detail in Describing Intervention/Exposure High Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? Yes Could Variation from Protocol have Compromised Study Findings? Cannot determine Outcome Assessors Masked? NR Care Provider Masked? No Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? Prospective documentation Outcomes Measured in Valid and Reliable Manner For main outcome (completing follow-up visit): retrospective self-report of patient For blood pressure: Objective, previously validated Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? Yes (30% vs. 22% attrition) Did Attrition Differ by More Than 15 Percentage Points After Randomization? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? Yes (by report) Does Analysis Control for Baseline Differences? NA Analysis Conducted on ITT Basis? No, completers analysis Any Post-Randomization Exclusions? Yes Conclusions Supported by Results? Yes Quality Rating Fair
Author Year Krieger et al., 2002; Krieger et al., 2005 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? Yes Assignment Randomized Yes Allocation of Randomization Adequately Concealed? Yes Level of Detail in Describing Intervention/Exposure Medium Usual Clinical Care Described? NA Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? Yes Could Variation from Protocol have Compromised Study Findings? No Outcome Assessors Masked? No Care Provider Masked? No Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? NR Outcomes Measured in Valid and Reliable Manner NR Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? No Did Attrition Differ by More Than 15 Percentage Points After Randomization? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? Yes Does Analysis Control for Baseline Differences? Yes Analysis Conducted on ITT Basis? Yes and no Any Post-Randomization Exclusions? Yes Conclusions Supported by Results? Yes Quality Rating Good
Author Year Levine et al., 2003 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized No Allocation of Randomization Adequately Concealed? NR Level of Detail in Describing Intervention/Exposure High Usual Clinical Care Described? NA Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? NA Could Variation from Protocol have Compromised Study Findings? Cannot determine Outcome Assessors Masked? NR Care Provider Masked? No Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? Prospective documentation Outcomes Measured in Valid and Reliable Manner Objective, validated Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? Yes - G1 38%, G2 43% Did Attrition Differ by More Than 15 Percentage Points After Randomization? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? Yes Does Analysis Control for Baseline Differences? NA Analysis Conducted on ITT Basis? Yes Any Post-Randomization Exclusions? Yes (G1 = 145, G2 = 173) Conclusions Supported by Results? Yes Quality Rating Fair
Author Year Lujanet al., 2007 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? Yes Assignment Randomized NR Allocation of Randomization Adequately Concealed? NR Level of Detail in Describing Intervention/Exposure Medium Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? NA Could Variation from Protocol have Compromised Study Findings? Yes (but only 1 subject crossed over from control to intervention, so minimal impact on results) Outcome Assessors Masked? Yes Care Provider Masked? NR Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? Objective measure, not validated Outcomes Measured in Valid and Reliable Manner Objective Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? No Did Attrition Differ by More Than 15 Percentage Points After Randomization? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? Cannot determine (for most characteristics because no table 1; most characteristics reported for entire sample rather than for each group; of note, mean Hgb A1c levels were different at baseline---8.71 vs. 7.71) Does Analysis Control for Baseline Differences? CD Analysis Conducted on ITT Basis? No Any Post-Randomization Exclusions? Yes (1) Conclusions Supported by Results? Yes Quality Rating Good
Author Year Mock et al., 2007 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Partially Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized NR (but subjects from same household were kept in same arm) Allocation of Randomization Adequately Concealed? NR Level of Detail in Describing Intervention/Exposure Medium Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? NA Could Variation from Protocol have Compromised Study Findings? Cannot determine Outcome Assessors Masked? No Care Provider Masked? No Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? NR Outcomes Measured in Valid and Reliable Manner Retrospective self-report Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? No Did Attrition Differ by More Than 15 Percentage Points After Randomization? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? Yes Does Analysis Control for Baseline Differences? NA Analysis Conducted on ITT Basis? Yes Any Post-Randomization Exclusions? Cannot tell Conclusions Supported by Results? Yes Quality Rating Fair
Author Year Morisky et al., 2002; Ward et al., 2000 Hypothesis/Aim/Objective of Study Described? No Criteria Clearly Stated? No Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized NR Allocation of Randomization Adequately Concealed? NR Level of Detail in Describing Intervention/Exposure High Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? No Could Variation from Protocol have Compromised Study Findings? Cannot determine Outcome Assessors Masked? NR Care Provider Masked? NR Patient Masked? NR | Interventions/Exposures Measured in Valid and Reliable Manner? NR Outcomes Measured in Valid and Reliable Manner Blood pressure measurement technique not reported Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? Yes (flow diagram/attrition not clearly reported, but Table 2 "BP in control" section indicates that was quite high) Did Attrition Differ by More Than 15 Percentage Points After Randomization? Cannot determine Baseline Characteristics Similar in Exposed/Comparison Cohorts? Cannot determine (they suggest that they are, but there is no Table 1 and baseline characteristics are not adequately reported) Does Analysis Control for Baseline Differences? NA Analysis Conducted on ITT Basis? No, completers analysis Any Post-Randomization Exclusions? Yes Conclusions Supported by Results? Partially (no discussion of effect of CHWs) Quality Rating Poor
Author Year Navarro et al., 1998; Navarro et al., 1995; Navarro et al., 2000 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? No Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized NR Allocation of Randomization Adequately Concealed? NR Level of Detail in Describing Intervention/Exposure High Usual Clinical Care Described? NA Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? No Could Variation from Protocol have Compromised Study Findings? No Outcome Assessors Masked? NR Care Provider Masked? No Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? Retrospective self-report Outcomes Measured in Valid and Reliable Manner Retrospective self-report Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? Yes Did Attrition Differ by More Than 15 Percentage Points After Randomization? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? Yes Does Analysis Control for Baseline Differences? Yes Analysis Conducted on ITT Basis? No Any Post-Randomization Exclusions? Cannot tell Conclusions Supported by Results? Yes Quality Rating Poor
Author Year Parker et al., 2008 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized Yes Allocation of Randomization Adequately Concealed? NR Level of Detail in Describing Intervention/Exposure High Usual Clinical Care Described? No Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? No Could Variation from Protocol have Compromised Study Findings? No Outcome Assessors Masked? No Care Provider Masked? No Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? Objective (some validated, some not) and retrospective self-report Outcomes Measured in Valid and Reliable Manner Objective (some validated, some not) and retrospective self-report Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? Yes (23% and 25%) Did Attrition Differ by More Than 15 Percentage Points After Randomization? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? Yes Does Analysis Control for Baseline Differences? Yes Analysis Conducted on ITT Basis? No Any Post-Randomization Exclusions? Yes (30) Conclusions Supported by Results? Yes Quality Rating Fair
Author Year Paskett et al., 2006; Katz et al., 2007 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? Yes Assignment Randomized Yes Allocation of Randomization Adequately Concealed? Yes Level of Detail in Describing Intervention/Exposure Medium Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? Yes Could Variation from Protocol have Compromised Study Findings? No Outcome Assessors Masked? Yes Care Provider Masked? Yes Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? Prospective documentation Outcomes Measured in Valid and Reliable Manner Objective Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? No Did Attrition Differ by More Than 15 Percentage Points After Randomization? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? Yes Does Analysis Control for Baseline Differences? NA Analysis Conducted on ITT Basis? Yes Any Post-Randomization Exclusions? Yes: 17 refused Conclusions Supported by Results? Yes Quality Rating Good
Author Year Pilote et al., 1996 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized Yes Allocation of Randomization Adequately Concealed? NR Level of Detail in Describing Intervention/Exposure Medium Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? NA Could Variation from Protocol have Compromised Study Findings? CD Outcome Assessors Masked? NR Care Provider Masked? NR Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? NR Outcomes Measured in Valid and Reliable Manner NR Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? CD Did Attrition Differ by More Than 15 Percentage Points After Randomization? CD Baseline Characteristics Similar in Exposed/Comparison Cohorts? Yes Does Analysis Control for Baseline Differences? NA Analysis Conducted on ITT Basis? Yes Any Post-Randomization Exclusions? Cannot tell Conclusions Supported by Results? Partially Quality Rating Fair
Author Year Rask t al., 2001; LeBaron et al., 2004 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Partially Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized NR Allocation of Randomization Adequately Concealed? NR Level of Detail in Describing Intervention/Exposure High Usual Clinical Care Described? No Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? No Could Variation from Protocol have Compromised Study Findings? CD Outcome Assessors Masked? NR Care Provider Masked? NR Patient Masked? NR | Interventions/Exposures Measured in Valid and Reliable Manner? Prospective documentation Outcomes Measured in Valid and Reliable Manner Objective Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? CD Did Attrition Differ by More Than 15 Percentage Points After Randomization? CD Baseline Characteristics Similar in Exposed/Comparison Cohorts? CD Does Analysis Control for Baseline Differences? CD Analysis Conducted on ITT Basis? CD Any Post-Randomization Exclusions? CD Conclusions Supported by Results? NR Quality Rating Good
Author Year Schuler et al., 2000 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? No Partially Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized No NR Allocation of Randomization Adequately Concealed? No NR Level of Detail in Describing Intervention/Exposure Low Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? No Yes: exclusion of families with a different home visiting component; multivariate analyses Could Variation from Protocol have Compromised Study Findings? Cannot determine Outcome Assessors Masked? Yes, but method not described Care Provider Masked? No Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? Retrospective self-report (patient/participant response) Outcomes Measured in Valid and Reliable Manner Some objective; others Retrospective self-report (patient/participant response) Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? No Did Attrition Differ by More Than 15 Percentage Points After Randomization? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? Yes Does Analysis Control for Baseline Differences? NA Analysis Conducted on ITT Basis? Kind of Yes Any Post-Randomization Exclusions? Yes Conclusions Supported by Results? Partially Quality Rating Fair
Author Year Silver et al., 1997 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized NR Allocation of Randomization Adequately Concealed? Yes (randomizer unaware of baseline responses & not involved with intervention) Level of Detail in Describing Intervention/Exposure Low Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? No Could Variation from Protocol have Compromised Study Findings? Cannot determine Outcome Assessors Masked? Yes, but method not described Not reported Care Provider Masked? No Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? Retrospective self-report (patient/participant response) Outcomes Measured in Valid and Reliable Manner Objective Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? No Did Attrition Differ by More Than 15 Percentage Points After Randomization? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? No: experimental group had significantly higher baseline PSI score Does Analysis Control for Baseline Differences? NA Yes Analysis Conducted on ITT Basis? Yes Any Post-Randomization Exclusions? Cannot tell Yes (22) Conclusions Supported by Results? Yes Quality Rating Fair
Author Year Sung et al., 1997; Sung et al., 1992 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? No Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized NR Allocation of Randomization Adequately Concealed? NR Level of Detail in Describing Intervention/Exposure Low Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? na Could Variation from Protocol have Compromised Study Findings? Cannot determine Outcome Assessors Masked? No Care Provider Masked? No Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? NR Outcomes Measured in Valid and Reliable Manner Retrospective self-report Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? Yes (G1 43%, G2 35%) Did Attrition Differ by More Than 15 Percentage Points After Randomization? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? Yes Does Analysis Control for Baseline Differences? NA Analysis Conducted on ITT Basis? Yes Any Post-Randomization Exclusions? No Conclusions Supported by Results? Yes Quality Rating Poor
Author Year Taylor et al., 2002 Hypothesis/Aim/ Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized Yes Allocation of Randomization Adequately Concealed? NR Level of Detail in Describing Intervention/Exposure High Usual Clinical Care Described? No Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? NA Could Variation from Protocol have Compromised Study Findings? No Outcome Assessors Masked? No Care Provider Masked? No Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? Retrospective self-report Outcomes Measured in Valid and Reliable Manner Objective, previously validated Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? No Did Attrition Differ by More Than 15 Percentage Points After Randomization? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? Yes Does Analysis Control for Baseline Differences? NA Analysis Conducted on ITT Basis? Yes Any Post-Randomization Exclusions? Cannot tell Conclusions Supported by Results? Yes Quality Rating Fair
Author Year Von Korff et al., 1998 Hypothesis/Aim/ Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized NR Allocation of Randomization Adequately Concealed? NR Level of Detail in Describing Intervention/Exposure Medium Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? NA Could Variation from Protocol have Compromised Study Findings? Cannot determine Outcome Assessors Masked? Yes, but method not described Care Provider Masked? No Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? NR Outcomes Measured in Valid and Reliable Manner Objective Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? No Did Attrition Differ by More Than 15 Percentage Points After Randomization? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? Yes Does Analysis Control for Baseline Differences? Yes Analysis Conducted on ITT Basis? Yes Any Post-Randomization Exclusions? No Conclusions Supported by Results? Partially Quality Rating Fair
Author Year Wolff et al., 1997 Morse et al., 1997 Hypothesis/Aim/ Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Assignment Randomized No Allocation of Randomization Adequately Concealed? NR Level of Detail in Describing Intervention/Exposure Low Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? Yes Could Variation from Protocol have Compromised Study Findings? Yes Outcome Assessors Masked? NR Care Provider Masked? No Patient Masked? No | Interventions/Exposures Measured in Valid and Reliable Manner? Retrospective self-report (patient/participant response) Outcomes Measured in Valid and Reliable Manner Retrospective self-report (patient/participant response) Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition from Any Group Exceed 20% After Randomization? Yes 85/165 Did Attrition Differ by More Than 15 Percentage Points After Randomization? Yes - 30+% Baseline Characteristics Similar in Exposed/Comparison Cohorts? Cannot determine Does Analysis Control for Baseline Differences? Cannot determine Analysis Conducted on ITT Basis? No Any Post-Randomization Exclusions? Cannot tell Conclusions Supported by Results? No Quality Rating Poor

Evidence Table C-3 Key Questions 1, 2, and 3: Quality Observational

Study Characteristics Background Inclusion/Exclusion Criteria Randomization Interventions/Exposure Contamination Blinding Soundness of Information | Follow-Up Analysis Comparability/Outcome
Author Year Barnes-Boyd et al., 2001 Hypothesis/Aim/ Objective of Study Described? No Criteria Clearly Stated? No Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Level of Detail in Describing Intervention/Exposure? Medium Is Usual Clinical Care Described? No Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? No Could Variation from Protocol have Compromised Study Findings? Cannot determine Outcome Assessors Blinded to Intervention/Exposure Status of Participants? No Interventions/Exposures Measured in Valid and Reliable Manner? Prospective documentation Outcomes Measured in Valid and Reliable Manner? NR | Same Length of Follow-up or Adjustment for Different Length of Follow-up? Cannot determine Is Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition for Any Group Exceed 20% After Allocation of Treatment? Yes (14% at 2 months and 44% at 11 months for REACH-Futures and 25% and 42% for REACH, respectively) Did Attrition Differ by More Than 15 Percentage Points After Allocation of Treatment? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? No Does Analysis Control for Baseline Differences? No Confounding and Modifying Variables Accounted for? No (no assessment of secular trend; this is a historical comparison) Analysis Conducted on ITT Basis? Yes Impact of Loss to Follow-up (or Differential Loss to Follow-up) Assessed? Cannot determine Statistical Methods Used to Assess Primary Outcomes Appropriate to Data? Yes For Cohort Studies Only, If Outcome has Greater than 10% Prevalence, is Risk Ratio and Relative Risk Calculated Directly? No (no RR reported) Does Study Report Appropriate Estimates of Random Variability in Data for Main Outcomes? No Conclusions Supported by Results? No Quality Rating Poor
Author Year Beckham et al., 2008 Hypothesis/Aim/ Objective of Study Described? Yes Criteria Clearly Stated? NA Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Level of Detail in Describing Intervention/Exposure? Medium Is Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? No Could Variation from Protocol have Compromised Study Findings? NA Outcome Assessors Blinded to Intervention/Exposure Status of Participants? No Interventions/Exposures Measured in Valid and Reliable Manner? Objective (clinical reports, lab findings, previously validated measures) Outcomes Measured in Valid and Reliable Manner? Objective (clinical reports, lab findings, previously validated measures) | Same Length of Follow-up or Adjustment for Different Length of Follow-up? No Is Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition for Any Group Exceed 20% After Allocation of Treatment? No Did Attrition Differ by More Than 15 Percentage Points After Allocation of Treatment? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? Yes Does Analysis Control for Baseline Differences? NA Confounding and Modifying Variables Accounted for? No Analysis Conducted on ITT Basis? No Impact of Loss to Follow-up (or Differential Loss to Follow-up) Assessed? NA Statistical Methods Used to Assess Primary Outcomes Appropriate to Data? Partially For Cohort Studies Only, If Outcome has Greater than 10% Prevalence, is Risk Ratio and Relative Risk Calculated Directly? NA Does Study Report Appropriate Estimates of Random Variability in Data for Main Outcomes? No Conclusions Supported by Results? Partially Quality Rating Fair
Author Year Bone et al., 1989 Hypothesis/Aim/ Objective of Study Described? Yes Criteria Clearly Stated? Partially Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Level of Detail in Describing Intervention/Exposure? Medium (odd that it is described in results rather than methods section) Is Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? NA Could Variation from Protocol have Compromised Study Findings? Yes Outcome Assessors Blinded to Intervention/Exposure Status of Participants? No Interventions/Exposures Measured in Valid and Reliable Manner? prospective documentation Outcomes Measured in Valid and Reliable Manner? Prospective documentation (return to ED for follow up visit) | Same Length of Follow-up or Adjustment for Different Length of Follow-up? CD Is Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition for Any Group Exceed 20% After Allocation of Treatment? No Did Attrition Differ by More Than 15 Percentage Points After Allocation of Treatment? Cannot determine (this is really just one prospective cohort, they did not a priori define analysis plan and only in results define those that CHWs were unable to reach as comparison group) Baseline Characteristics Similar in Exposed/Comparison Cohorts? No or cannot determine, not reported Does Analysis Control for Baseline Differences? Cannot determine, no description of analysis Confounding and Modifying Variables Accounted for? CD Analysis Conducted on ITT Basis? No Impact of Loss to Follow-up (or Differential Loss to Follow-up) Assessed? No Statistical Methods Used to Assess Primary Outcomes Appropriate to Data? NA, methods not reported For Cohort Studies Only, If Outcome has Greater than 10% Prevalence, is Risk Ratio and Relative Risk Calculated Directly? NA Does Study Report Appropriate Estimates of Random Variability in Data for Main Outcomes? No Conclusions Supported by Results? Partially Quality Rating Poor
Author Year Caulfield et al., 1998 Hypothesis/Aim/ Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Level of Detail in Describing Intervention/Exposure? Medium Is Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? Yes Could Variation from Protocol have Compromised Study Findings? Yes Outcome Assessors Blinded to Intervention/Exposure Status of Participants? No Interventions/Exposures Measured in Valid and Reliable Manner? Objective measure, not validated Outcomes Measured in Valid and Reliable Manner? Retrospective self-report (patient/participant response) | Same Length of Follow-up or Adjustment for Different Length of Follow-up? No Is Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition for Any Group Exceed 20% After Allocation of Treatment? Yes Did Attrition Differ by More Than 15 Percentage Points After Allocation of Treatment? Yes Baseline Characteristics Similar in Exposed/Comparison Cohorts? No Does Analysis Control for Baseline Differences? Yes Confounding and Modifying Variables Accounted for? Yes Analysis Conducted on ITT Basis? No Impact of Loss to Follow-up (or Differential Loss to Follow-up) Assessed? Yes a bit Statistical Methods Used to Assess Primary Outcomes Appropriate to Data? Partially For Cohort Studies Only, If Outcome has Greater than 10% Prevalence, is Risk Ratio and Relative Risk Calculated Directly? NA Does Study Report Appropriate Estimates of Random Variability in Data for Main Outcomes? Yes Conclusions Supported by Results? Partially Quality Rating Poor
Author Year Earp et al., 2002 Hypothesis/Aim/ Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? Partially Level of Detail in Describing Intervention/Exposure? Low Is Usual Clinical Care Described? No Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? Yes Could Variation from Protocol have Compromised Study Findings? NA Outcome Assessors Blinded to Intervention/Exposure Status of Participants? No Interventions/Exposures Measured in Valid and Reliable Manner? NR Outcomes Measured in Valid and Reliable Manner? Retrospective self-report | Same Length of Follow-up or Adjustment for Different Length of Follow-up? Yes Is Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition for Any Group Exceed 20% After Allocation of Treatment? No Did Attrition Differ by More Than 15 Percentage Points After Allocation of Treatment? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? No (for income, lack of medical visits, perceived barriers to screening, knowledge about breast cancer) Does Analysis Control for Baseline Differences? Yes Confounding and Modifying Variables Accounted for? Yes Analysis Conducted on ITT Basis? Yes Impact of Loss to Follow-up (or Differential Loss to Follow-up) Assessed? No Statistical Methods Used to Assess Primary Outcomes Appropriate to Data? Partially For Cohort Studies Only, If Outcome has Greater than 10% Prevalence, is Risk Ratio and Relative Risk Calculated Directly? NA Does Study Report Appropriate Estimates of Random Variability in Data for Main Outcomes? Yes Conclusions Supported by Results? Yes Quality Rating Poor
Author Year Erwin et al., 1997 Hypothesis/Aim/ Objective of Study Described? Yes Criteria Clearly Stated? No Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Level of Detail in Describing Intervention/Exposure? Medium Is Usual Clinical Care Described? No Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? No Could Variation from Protocol have Compromised Study Findings? Cannot determine Outcome Assessors Blinded to Intervention/Exposure Status of Participants? No Interventions/Exposures Measured in Valid and Reliable Manner? Objective measure, not validated Outcomes Measured in Valid and Reliable Manner? Retrospective self-report (patient/participant response) | Same Length of Follow-up or Adjustment for Different Length of Follow-up? No Is Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition for Any Group Exceed 20% After Allocation of Treatment? No Did Attrition Differ by More Than 15 Percentage Points After Allocation of Treatment? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? No Does Analysis Control for Baseline Differences? Yes Confounding and Modifying Variables Accounted for? Partially Analysis Conducted on ITT Basis? NA Impact of Loss to Follow-up (or Differential Loss to Follow-up) Assessed? No Statistical Methods Used to Assess Primary Outcomes Appropriate to Data? Yes For Cohort Studies Only, If Outcome has Greater than 10% Prevalence, is Risk Ratio and Relative Risk Calculated Directly? NA Does Study Report Appropriate Estimates of Random Variability in Data for Main Outcomes? Yes Conclusions Supported by Results? Yes Quality Rating Fair
Author Year Forst et al., 2004 Hypothesis/Aim/ Objective of Study Described? Yes Criteria Clearly Stated? Partially Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Level of Detail in Describing Intervention/Exposure? Medium Is Usual Clinical Care Described? Yes Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? No Could Variation from Protocol have Compromised Study Findings? No (authors do not describe any variation, or lack of variation, from protocol; however, there is fair potential for contamination) Outcome Assessors Blinded to Intervention/Exposure Status of Participants? No Interventions/Exposures Measured in Valid and Reliable Manner? Objective, not validated Outcomes Measured in Valid and Reliable Manner? Retrospective self-report | Same Length of Follow-up or Adjustment for Different Length of Follow-up? Yes Is Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition for Any Group Exceed 20% After Allocation of Treatment? Yes - about 30% overall (note: 83 subjects were excluded at end b/c one CHW admitted to completing questionnaires herself) Did Attrition Differ by More Than 15 Percentage Points After Allocation of Treatment? Cannot determine Baseline Characteristics Similar in Exposed/Comparison Cohorts? Cannot determine Does Analysis Control for Baseline Differences? NA Confounding and Modifying Variables Accounted for? No Analysis Conducted on ITT Basis? Yes Impact of Loss to Follow-up (or Differential Loss to Follow-up) Assessed? No Statistical Methods Used to Assess Primary Outcomes Appropriate to Data? Yes For Cohort Studies Only, If Outcome has Greater than 10% Prevalence, is Risk Ratio and Relative Risk Calculated Directly? NA Does Study Report Appropriate Estimates of Random Variability in Data for Main Outcomes? No Conclusions Supported by Results? Partially Quality Rating Poor
Author Year Frate et al., 1985 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? No Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Level of Detail in Describing Intervention/Exposure? Low Is Usual Clinical Care Described? No Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? No Could Variation from Protocol have Compromised Study Findings? NA Outcome Assessors Blinded to Intervention/Exposure Status of Participants? No Interventions/Exposures Measured in Valid and Reliable Manner? Objective Outcomes Measured in Valid and Reliable Manner? Objective | Same Length of Follow-up or Adjustment for Different Length of Follow-up? NA Is Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition for Any Group Exceed 20% After Allocation of Treatment? Cannot determine Did Attrition Differ by More Than 15 Percentage Points After Allocation of Treatment? Cannot determine Baseline Characteristics Similar in Exposed/Comparison Cohorts? Cannot determine Does Analysis Control for Baseline Differences? NA Confounding and Modifying Variables Accounted for? No Analysis Conducted on ITT Basis? No Impact of Loss to Follow-up (or Differential Loss to Follow-up) Assessed? No Statistical Methods Used to Assess Primary Outcomes Appropriate to Data? No For Cohort Studies Only, If Outcome has Greater than 10% Prevalence, is Risk Ratio and Relative Risk Calculated Directly? NA Does Study Report Appropriate Estimates of Random Variability in Data for Main Outcomes? No Conclusions Supported by Results? No Quality Rating Extra Poor
Author Year Nacion et al., 2000 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Level of Detail in Describing Intervention/Exposure? Low Is Usual Clinical Care Described? NA Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? NA Could Variation from Protocol have Compromised Study Findings? NA Outcome Assessors Blinded to Intervention/Exposure Status of Participants? No Interventions/Exposures Measured in Valid and Reliable Manner? Prospective documentation Outcomes Measured in Valid and Reliable Manner? NR | Same Length of Follow-up or Adjustment for Different Length of Follow-up? NA Is Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition for Any Group Exceed 20% After Allocation of Treatment? No Did Attrition Differ by More Than 15 Percentage Points After Allocation of Treatment? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? No Does Analysis Control for Baseline Differences? No Confounding and Modifying Variables Accounted for? Cannot determine Analysis Conducted on ITT Basis? Yes Impact of Loss to Follow-up (or Differential Loss to Follow-up) Assessed? NA Statistical Methods Used to Assess Primary Outcomes Appropriate to Data? Yes For Cohort Studies Only, If Outcome has Greater than 10% Prevalence, is Risk Ratio and Relative Risk Calculated Directly? NA Does Study Report Appropriate Estimates of Random Variability in Data for Main Outcomes? No Conclusions Supported by Results? Yes Quality Rating Fair
Author Year Sauaia et al., 2007; Welsh et al., 2005 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Level of Detail in Describing Intervention/Exposure? Medium Is Usual Clinical Care Described? No Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? No Could Variation from Protocol have Compromised Study Findings? NA Outcome Assessors Blinded to Intervention/Exposure Status of Participants? No Interventions/Exposures Measured in Valid and Reliable Manner? Prospective documentation Outcomes Measured in Valid and Reliable Manner? objective measure | Same Length of Follow-up or Adjustment for Different Length of Follow-up? NA Is Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition for Any Group Exceed 20% After Allocation of Treatment? NA Did Attrition Differ by More Than 15 Percentage Points After Allocation of Treatment? NA Baseline Characteristics Similar in Exposed/Comparison Cohorts? CD Does Analysis Control for Baseline Differences? NA Confounding and Modifying Variables Accounted for? Partially Analysis Conducted on ITT Basis? Yes Impact of Loss to Follow-up (or Differential Loss to Follow-up) Assessed? NA Statistical Methods Used to Assess Primary Outcomes Appropriate to Data? Yes For Cohort Studies Only, If Outcome has Greater than 10% Prevalence, is Risk Ratio and Relative Risk Calculated Directly? NA Does Study Report Appropriate Estimates of Random Variability in Data for Main Outcomes? No Conclusions Supported by Results? Yes Quality Rating Fair
Author Year Schwarz et al., 1993 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Level of Detail in Describing Intervention/Exposure? Medium Is Usual Clinical Care Described? No Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? Not really Could Variation from Protocol have Compromised Study Findings? Yes Outcome Assessors Blinded to Intervention/Exposure Status of Participants? No: “health department personnel were not blinded to intervention or control status of each household” Interventions/Exposures Measured in Valid and Reliable Manner? Objective measure, not validated Outcomes Measured in Valid and Reliable Manner? Objective measure, not validated | Same Length of Follow-up or Adjustment for Different Length of Follow-up? NA Is Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition for Any Group Exceed 20% After Allocation of Treatment? No Did Attrition Differ by More Than 15 Percentage Points After Allocation of Treatment? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? No Does Analysis Control for Baseline Differences? No Confounding and Modifying Variables Accounted for? No Analysis Conducted on ITT Basis? No Impact of Loss to Follow-up (or Differential Loss to Follow-up) Assessed? No Statistical Methods Used to Assess Primary Outcomes Appropriate to Data? Partially For Cohort Studies Only, If Outcome has Greater than 10% Prevalence, is Risk Ratio and Relative Risk Calculated Directly? NA Does Study Report Appropriate Estimates of Random Variability in Data for Main Outcomes? Yes Conclusions Supported by Results? Partially Quality Rating Poor
Author Year St. James et al., 1999 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Partially Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Level of Detail in Describing Intervention/Exposure? Low Is Usual Clinical Care Described? No Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? No Could Variation from Protocol have Compromised Study Findings? Yes Outcome Assessors Blinded to Intervention/Exposure Status of Participants? Yes Interventions/Exposures Measured in Valid and Reliable Manner? Objective measure, not validated Outcomes Measured in Valid and Reliable Manner? Objective | Same Length of Follow-up or Adjustment for Different Length of Follow-up? NA Is Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition for Any Group Exceed 20% After Allocation of Treatment? NA Did Attrition Differ by More Than 15 Percentage Points After Allocation of Treatment? NA Baseline Characteristics Similar in Exposed/Comparison Cohorts? CD Does Analysis Control for Baseline Differences? CD Confounding and Modifying Variables Accounted for? CD Analysis Conducted on ITT Basis? Yes Impact of Loss to Follow-up (or Differential Loss to Follow-up) Assessed? NA Statistical Methods Used to Assess Primary Outcomes Appropriate to Data? Yes For Cohort Studies Only, If Outcome has Greater than 10% Prevalence, is Risk Ratio and Relative Risk Calculated Directly? No Does Study Report Appropriate Estimates of Random Variability in Data for Main Outcomes? No Conclusions Supported by Results? No Quality Rating Fair
Author Year Tessaro et al., 1997; Navaie-Waliser, et al., 2000 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? Yes Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Level of Detail in Describing Intervention/Exposure? Low Is Usual Clinical Care Described? No Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? Yes Could Variation from Protocol have Compromised Study Findings? Cannot determine Outcome Assessors Blinded to Intervention/Exposure Status of Participants? NR Interventions/Exposures Measured in Valid and Reliable Manner? NR Outcomes Measured in Valid and Reliable Manner? Combination of validated scales/questionnaires and responses to interview questions | Same Length of Follow-up or Adjustment for Different Length of Follow-up? Yes Is Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? Yes Did Attrition for Any Group Exceed 20% After Allocation of Treatment? Yes - G1 34%; G2 40% Did Attrition Differ by More Than 15 Percentage Points After Allocation of Treatment? No Baseline Characteristics Similar in Exposed/Comparison Cohorts? No, differences in age, race, marital status, education, annual family income. (Baseline data for a number of other important factors NR) Does Analysis Control for Baseline Differences? Yes Confounding and Modifying Variables Accounted for? Partially Analysis Conducted on ITT Basis? Yes Impact of Loss to Follow-up (or Differential Loss to Follow- up) Assessed? No Statistical Methods Used to Assess Primary Outcomes Appropriate to Data? Partially (a great number of analyses conducted w/multiple comparisons and several regressions; no description of primary outcomes; no sample size calculations; no adjustment for multiple comparisons; potential data mining) For Cohort Studies Only, If Outcome has Greater than 10% Prevalence, is Risk Ratio and Relative Risk Calculated Directly? No Does Study Report Appropriate Estimates of Random Variability in Data for Main Outcomes? Yes Conclusions Supported by Results? No (conclusions do not reflect potential biases in results) Quality Rating Poor
Author Year Wendell et al., 2003 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? NA Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? No Level of Detail in Describing Intervention/Exposure? Medium Is Usual Clinical Care Described? NA Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? Yes Could Variation from Protocol have Compromised Study Findings? Cannot determine Outcome Assessors Blinded to Intervention/Exposure Status of Participants? No Interventions/Exposures Measured in Valid and Reliable Manner? Objective measure, not validated Outcomes Measured in Valid and Reliable Manner? Objective measure, not validated | Same Length of Follow-up or Adjustment for Different Length of Follow-up? NA Is Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? NA Did Attrition for Any Group Exceed 20% After Allocation of Treatment? NA Did Attrition Differ by More Than 15 Percentage Points After Allocation of Treatment? NA Baseline Characteristics Similar in Exposed/Comparison Cohorts? Yes Does Analysis Control for Baseline Differences? NA Confounding and Modifying Variables Accounted for? Yes Analysis Conducted on ITT Basis? NA Impact of Loss to Follow-up (or Differential Loss to Follow-up) Assessed? NA Statistical Methods Used to Assess Primary Outcomes Appropriate to Data? Yes For Cohort Studies Only, If Outcome has Greater than 10% Prevalence, is Risk Ratio and Relative Risk Calculated Directly? NA Does Study Report Appropriate Estimates of Random Variability in Data for Main Outcomes? Yes Conclusions Supported by Results? Yes Quality Rating Fair
Author Year Wilson et al., 2008 Hypothesis/Aim/Objective of Study Described? Yes Criteria Clearly Stated? No Power Analysis or Some Other Basis for Determining Adequacy of Study Group Sizes for Primary Outcome(s)? Yes Level of Detail in Describing Intervention/Exposure? Low Is Usual Clinical Care Described? NA Researchers Rule out Impact from Unintended Intervention/Exposure that Might Bias Results? No Could Variation from Protocol have Compromised Study Findings? NA Outcome Assessors Blinded to Intervention/Exposure Status of Participants? No Interventions/Exposures Measured in Valid and Reliable Manner? NR Outcomes Measured in Valid and Reliable Manner? retrospective self-report | Same Length of Follow-up or Adjustment for Different Length of Follow-up? NA Is Length of Time Following Intervention/Exposure Sufficient to Support Conclusions? NA Did Attrition for Any Group Exceed 20% After Allocation of Treatment? NA Did Attrition Differ by More Than 15 Percentage Points After Allocation of Treatment? NA Baseline Characteristics Similar in Exposed/Comparison Cohorts? NR Does Analysis Control for Baseline Differences? NA Confounding and Modifying Variables Accounted for? No Analysis Conducted on ITT Basis? NA Impact of Loss to Follow-up (or Differential Loss to Follow-up) Assessed? NA Statistical Methods Used to Assess Primary Outcomes Appropriate to Data? Partially For Cohort Studies Only, If Outcome has Greater than 10% Prevalence, is Risk Ratio and Relative Risk Calculated Directly? NA Does Study Report Appropriate Estimates of Random Variability in Data for Main Outcomes? Yes Conclusions Supported by Results? Yes Quality Rating Poor

Evidence Table C-4 Key Question 4 and 4a

Study Characteristics Setting | Community Health Worker | Training Characteristics
Author Year Balcazar et al., 2006 Trial Name Salud Para Su Corazon-NCLR Objective or Aim To promote heart-healthy behaviors among Latinos Geography Escondido CA, Chicago IL, Ojo Caliente NM Organization Latino communities Type of Community Latino communities Start Date 2000 Health Condition of Interest Cardiovascular disease | Title of CHW Promotora Relationship with Community NR CHW (N) 29 Supervision of CHW NR Prior Training NR Type of Service Education sessions Type of Educational Materials Used Handouts, recipes, videos, actor scripts, games Duration of Interaction with Clients 7 2-hour sessions over 6 months Length of Follow-up 1 year | Eligibility for CHW Training NR Input of CHW in Curriculum Development None Training on Cultural Competency NR (curriculum does offer “cultural and language appropriate instructional methods” but details NR) Training on Recruitment/Retention Process NR Training on Intake/Assessment NR Training on Protocol Delivery NR Training on Health Topic NR Training on Evaluation NR Other Training NR Other Training Content; Instructional Method; Number of Sessions; Testing NR Name of Curriculum Your Heart, Your life Availability of Curriculum Available online Evaluation and Testing Results of Curriculum closed-format pre-post test scores reported a score of 74% for pretest and 100% correct for posttest (n = 11). Differences in pre-post promotora knowledge scores changes (N = 29) were statistically (P < 0.05) but data reported in bar graph only. Certification NR Other Pertinent Information NA Are Particular Training Characteristics Associate with Improved Outcomes? NR
Author Year Beck et al., 2007 Trial Name Center for Health Communities' cancer education program Objective or Aim Train trainer in cancer education Geography Milwaukee County Organization African-American churches Type of Community African-American churches Start Date 2002 Health Condition of Interest Cancer prevention | Title of CHW Church Health Action Team (CHAT) member Relationship with Community Respected member of church congregation CHW (N) 6 (2 from each of 3 participating churches) Supervision of CHW NR Prior Training NR Type of Service Small group educational presentations Type of Educational Materials Used PowerPoint slides, handouts, brochures Duration of Interaction with Clients 4 60-minute presentations Length of Follow-up NR | Eligibility for CHW Training Member of congregation, well-respected, formal or informal leader, expressed enthusiasm for project Input of CHW in Curriculum Development None Training on Cultural Competency NR Training on Recruitment/Retention Process NR Training on Intake/Assessment NR Training on Protocol Delivery NR Training on Health Topic NR Training on Evaluation NR Other Training 2 90-minute train-the-trainer workshops Other Training Content; Instructional Method; Number of Sessions; Testing NR Name of Curriculum NR Availability of Curriculum NR Evaluation and Testing Results of Curriculum Pre-post % correct Ability to define cancer: (1)General 89/93 (2)Breast 79/86 (3)Colon 15/57 (4)Prostate 80/75 Ability to identify signs/symptoms of cancer: (1) NA/NA (2) 71/88 (3) 81/93 (4) 40/75 Ability to identify screening recommendations: (1) NA/NA (2) 67/67 (3) NA/NA (4) 80/75 Ability to identify risk factors: (1) 59/85 (2) 54/92 (3) 19/89 (4) 40/75 Ability to identify strategies to reduce cancer risk: (1) 70/78 (2) 8/33 (3) 92/96 (4) 20/75 Certification "Certificate of completion" at 2nd training session Other Pertinent Information Results reported for 1 church only; CHWs presented 3 of modules while pastor presented 4th Are Particular Training Characteristics Associate with Improved Outcomes? NR
Author Year Bell, et al., 1999 Trial Name Abuela Project Objective or Aim To train Hispanic women to make queso fresco that was authentic in taste and texture but did not use raw milk in an effort to reduce incidence of Salmonella serotype Typhimurium infections resulting from eating queso fresco made from raw milk. Geography Yakima County, Washington Organization Hispanic communities Type of Community Hispanics Start Date 1997 Health Condition of Interest Salmonella | Title of CHW Abuela educators Relationship with Community Shared ethnicity CHW (N) 15 Supervision of CHW NR Prior Training NR Type of Service Workshop, After training, each CHW singed contract indicating willingness to teach at least 15 members of community Type of Educational Materials Used Pamphlet, Duration of Interaction with Clients 1 workshop Length of Follow-up NR | Eligibility for CHW Training Older Hispanic women from Yakima County Input of CHW in Curriculum Development None; however, curriculum was developed with input from respected Hispanic woman from Yakima community Training on Cultural Competency NR Training on Recruitment/Retention Process NR Training on Intake/Assessment NR Training on Protocol Delivery NR Training on Health Topic NR Training on Evaluation NR Other Training Workshops on how to make new queso fresco recipe (i.e., w/o raw milk) Other Training Content; Instructional Method; Number of Sessions; Testing Training sessions were hands-on and interactive; participants encouraged to ask questions & make comments Other Training Content; Instructional Method; Number of Sessions; Testing NR Name of Curriculum Abuela Project Availability of Curriculum Pamphlet available Evaluation and Testing Results of Curriculum Pretraining/post-training: recognized health risks associated with eating unpasteurized milk and cheese: 10/14; 14/15 Make queso fresco with fresh unpasteurized milk: 6/12; 1/15. Certification No Other Pertinent Information NA Are Particular Training Characteristics Associate with Improved Outcomes? NR
Author Year Kuhajda et al., 2006 Trial Name Pine Apple Heart Disease and Stroke Project Objective or Aim To train CHWs for heart disease and stroke and in skills for counseling and assessing high-risk women in Pine Apple clinic. Geography Pine Apple, Alabama Organization African American women in rural southern community Type of Community African American women in rural southern community Start Date NR Health Condition of Interest Cardiovascular disease | Title of CHW Counseling CHW; Assessment CHW Relationship with Community African American women with experience as community health volunteers in county CHW (N) 4 Supervision of CHW NR Prior Training Trained as community health advisors through U of Alabama-Birmingham; all had 10 yrs experience as community health volunteers Type of Service Counseling CHWs counseled clinic patients using project manual; Assessment CHWs assessed future patients before and after counseling sessions Type of Educational Materials Used NR Duration of Interaction with Clients NR Length of Follow-up NR | Eligibility for CHW Training Chosen from a pool of CHWs trained as community health advisers through U of Alabama; expert advisory panel member assisted in selection Input of CHW in Curriculum Development CHWs shared ideas and concerns about training content and implementation of training sessions at a preliminary planning meeting Training on Cultural Competency NR Training on Recruitment/Retention Process NR Training on Intake/Assessment NR Training on Protocol Delivery Health education counseling; role-played cancer screening counseling sessions and CVD counseling sessions Training on Health Topic NR Training on Evaluation Topics addressed in training included CVD; Developing action plans (heart attack, congestive heart failure, stroke); High blood pressure; tobacco control; Cancer (lung, colorectal, breast, cervical) Other Training NR Name of Curriculum Training used revised revised Women's Wellness Sourcebook Module III: Heart and Stroke Availability of Curriculum Yes--revised manuals on cancer & stroke served as guide for training Evaluation and Testing Results of Curriculum Counseling CHWs' responses on pre-post training questionnaires showed increases in knowledge and self-reported behaviors in each of following areas: heart disease and stroke prevention strategies, cancer prevention strategies, heart attack or stroke signs and symptoms, cancer signs and symptoms, current heart disease and stroke prevention activities, current cancer prevention activities. Data reported in bar graph only. Certification NR Other Pertinent Information 4 week training period; counseling CHWs required to be present for entire 4-wk period (except 2 half days devoted to training assessment CHWs). A variety of media and text materials usd to simulate active participation Are Particular Training Characteristics Associate with Improved Outcomes? NR
Author Year Martinez-Bristow et al., 2006 Trial Name Tobacco Free El Paso Objective or Aim To train Spanish speaking counselors to deliver tobacco cessation interventions. Geography El Paso Organization Neighborhood clinics Type of Community Spanish-speaking populations Start Date 2003 Health Condition of Interest Tobacco cessation | Title of CHW Promotores Relationship with Community Spanish speaking members of community CHW (N) NR (89 participants in total, but 5% were healthcare professionals; baseline data collected for 74) Supervision of CHW NR Prior Training NR Type of Service Counseling Type of Educational Materials Used NR Duration of Interaction with Clients NR Length of Follow-up NR | Eligibility for CHW Training NR (training was open to employees of certain clinics, healthcare professionals as well as promotores) Input of CHW in Curriculum Development Curriculum taken from University of Arizona's Healthcare Partnership which was developed in 1996 Training on Cultural Competency NR Training on Recruitment/Retention Process Client recruitment was addressed in level 2 (Treatment Specialist) training; content, method, # of sessions NR Training on Intake/Assessment NR Training on Protocol Delivery NR Training on Health Topic Nicotine addiction Training on Evaluation NR Other Training 5 days of training for each level of certification Other Training Content; Instructional Method; Number of Sessions; Testing NR Name of Curriculum NR Availability of Curriculum Available through U of Arizona developed website; no separate curriculum developed for Tobacco Free El Paso-- curriculum "borrowed" directly from U of A Evaluation and Testing Results of Curriculum Results from pre-posttest measuring self-confidence suggest that participants understood training material; however data NR. Mean satisfaction scores (1 = definitely not confident to 5 = definitely confident) high for recipients of each certification: beginner: 4.8, intermediate: 4.7, advanced: 4.6 Certification 3 certifications offered: introductory (Basic Skills to Stop Using Tobacco); intermediate (Treatment Specialist); advanced (Leave Addiction) Other Pertinent Information NA Are Particular Training Characteristics Associate with Improved Outcomes? NR
Author Year Navarro et al., 2007 Trial Name Por La Vida Cuidandome Objective or Aim Train community health advisors to conduct interactive educational group sessions and train-the-trainer (through "learning partners" Geography San Diego, CA Organization Latino communities Type of Community Women with low level of acculturation in low socioeconomic Latino communities Start Date 1996 Health Condition of Interest Breast & cervical cancer | Title of CHW Consejeras Relationship with Community Part of local Latino community CHW (N) 17 consejeras, 285 primary participants, 222 learning partners Supervision of CHW NR Prior Training NR Type of Service Interactive educational group sessions, recruiting women from local community to be primary participants in these sessions Type of Educational Materials Used Manual to guide sessions Duration of Interaction with Clients 12 weekly sessions Length of Follow-up 6 months after pretest | Eligibility for CHW Training NR Input of CHW in Curriculum Development Developed over time & preveiously implement, so no Training on Cultural Competency NR Training on Recruitment/Retention Process There were 5 2-hour sessions covering recruitment strategies and role playing practice to lead sessions Training on Intake/Assessment NR Training on Protocol Delivery NR Training on Health Topic Manual had sessions for understanding female body, breast cancer, Pap test, breast health, risks Training on Evaluation NR Other Training Referral, communication skills Other Training Content; Instructional Method; Number of Sessions; Testing NR Name of Curriculum Por La Vida Cuidandomje, Taking Care of Myself: Women and Cancer Availability of Curriculum NR Evaluation and Testing Results of Curriculum Changes in knowledge & behavior pre/post test for primary participants; & learning partners Names following test for breast/cervical cancer early detection: BSE 58.6/74.7; 46.4/56.3 Clinical breast exam: 29.1/28.8; 28.8/20.7 Mammography: 49.8/71.2; 45.0/63.1 Pap test 84.6/91.9/79.3/85.1 Knows BSE: 90.5/99.3; 82.4/93.2 Knows mammography recs: 32.3/55.8; 27.4/38.1 Names ≥1 breast cancer symptom: 75.1/96.8; 70.3/94.1 Names ≥1 txt for breast cancer: 40.0/65.6; 27.9/45.0 Names ≥1 risk factor: 8.1/16.5; 6.8/7.2 Names ≥1 factor for cervical cancer: 30.9/59.6; 24.3/35.1 BSE in pasat month: 62.3/87.4; 55.9/71.5 Mammography ever: 63.3/70.0; 66.7/68.3 Pap test ever: 92.3/97.9; 88.3/92.8 Certification No Other Pertinent Information 14 program sessions (12 weekly sessions + 2 monthly session) plus 5 additional 2-hour sessions covering recruitment strategies and role playing practice to lead sessions Are Particular Training Characteristics Associate with Improved Outcomes? NR
Author Year Perez, 2006 Trial Name Northern Manhattan Community Voices Collaborative Objective or Aim To train community health workers, focusing on facilitating insurance enrollment, child immunization, and asthma management Geography Northern Manhattan Organization Neighborhoods Type of Community Northern Manhattan - Washington Heights, Inwood, and Harlem, comprising low income communities and/or racial and ethnic minorities (Dominican, African-American) Start Date 2000 Health Condition of Interest (1) health insurance (2) child immunizaations (3) asthma management | Title of CHW CHW Relationship with Community Live in community or a nearby neighborhood; share cultural & ethnic traditions with program participants CHW (N) # trained between 2000 & 2005: (1) 88 (2) 792 (3 624 Supervision of CHW NR Prior Training NR Type of Service Community-wide health promotion activities; serve as bridge to primary health care provider Type of Educational Materials Used NR Duration of Interaction with Clients NR Length of Follow-up varied | Eligibility for CHW Training Reside in community; shared culturual & enthic traditions with those they'll be serving; experience with programs offered by organization; good people skills; committed to community development Input of CHW in Curriculum Development NR Training on Cultural Competency Yes but not described Training on Recruitment/Retention Process NR Training on Intake/Assessment Yes but not described Training on Protocol Delivery Yes but not described Training on Health Topic Yes but not described Training on Evaluation Yes but not described (one of 7 core modules) Other Training Content; Instructional Method; Number of Sessions; Testing NR Name of Curriculum NR Availability of Curriculum NR Evaluation and Testing Results of Curriculum Gains in competency and knowledge (pre/post): (1) 24%/72% (gain = 48%; % change = 200; n tested = 61) (2) 83%/96% (gain-48%; %change = 16; n tested = 472) (3) 63%/83% (gain = 20%; %change = 32; n tested = 499) Certification NR Other Pertinent Information NA Are Particular Training Characteristics Associate with Improved Outcomes? NR
Author Year Williams, 1996 Trial Name NR Objective or Aim To raise awareness of & increase participation of older African-Americans in health promotion activities Geography Atlanta & Fort Valley Georgia Organization Older African-Americans Type of Community large urban & small township Start Date 1992 Health Condition of Interest Health promotion & education | Title of CHW Lay health educator Relationship with Community Older adult community members CHW (N) 47 Supervision of CHW Program outreach coordinators Prior Training NR Type of Service Conduct or facilitate at least 1 health promotion session/month & disseminate health ed materials through at least 1 of grassroots channels Type of Educational Materials Used Leaflets, brochures, pamphlets Duration of Interaction with Clients 1 group session/month Length of Follow-up NR | Eligibility for CHW Training Older ( > 55) living in target communities; expected to be knowledgeable about community, have history of volunteering, demonstrate good communication skills & ability to establish rapport with target population; nonsmokers of moderate weight, have at least 8th grade education Input of CHW in Curriculum Development None Training on Cultural Competency NR Training on Recruitment/Retention Process NR Training on Intake/Assessment NR Training on Protocol Delivery NR Training on Health Topic NR Training on Evaluation NR Other Training Training divided into 3 categories: chronic disease education & self-care, lifestyle education, and consumer education. Topics for these categories developed into 12 training modules Other Training Content; Instructional Method; Number of Sessions; Testing NR Name of Curriculum NR Availability of Curriculum NR Evaluation and Testing Results of Curriculum Obtained score ≥ 80 on pre and posttest for hypertension & diabetes training sessions: G1: 32%/60% G2: 11%/72% G3: 28%/93% Certification No Other Pertinent Information NA Are Particular Training Characteristics Associate with Improved Outcomes? NR
Author Year Yu et al., 2007 Trial Name NR Objective or Aim To inrease self-efficacy of HLAs in conducting breast cancer screening promotion Geography Southeast Michigan Organization Chinese communities Type of Community Chinese American women Start Date Health Condition of Interest Breast cancer | Title of CHW Lay health advisor (LHA) Relationship with Community Shared language CHW (N) 79 (10 others were eligible but unable to complete training program) Supervision of CHW NR Prior Training NR with respect to breast cancer screening; however-- Graduate degree: 67.4% College degree: 30.3% High school education: 2.2% Type of Service NR Type of Educational Materials Used NR Duration of Interaction with Clients NR (Phase I only) Length of Follow-up NR | Eligibility for CHW Training Adults bilingual in English & Chinese; at least a high school diploma; demonstrated enthusiasm for helping others Input of CHW in Curriculum Development Community leaders gave input to training materials; first-tier LHAs pretested training manual & Web site and provided comments for final version Training on Cultural Competency NR (but point out critical imporantance of a culturally competent program for this population) Training on Recruitment/Retention Process NR Training on Intake/Assessment NR Training on Protocol Delivery NR Training on Health Topic NR Training on Evaluation NR Other Training Training manual had 9 chapters + 5 appendices (1 was a bilingual glossary of medical terms); content includes socieodemographi characteristics & special health concerns, outreach strategies, effective communication skills for promoting screening. Also a web site, PowerPointslides and audio recordings available Other Training Content; Instructional Method; Number of Sessions; Testing 3-month self-study of training materials. program included both on-site instruction and materials on paper as well as on Web sites or CDs for self-paced study. Name of Curriculum Name of Curriculum Training manual: Helping Women Fight Breast Cancer Availability of Curriculum Through U of Michigan HAAP Evaluation and Testing Results of Curriculum Change in trainees' knowledge & self-efficacy Knowledge-Mean # of correct answers pre (SD)/post (SD): 6 (1.4)/8 (1.1), P < 0.001 Self-efficacy-mean score pre (SD)/post (SD): 61.0 (11.5)/65.0 (9.2), P = 0.016 Certification No Other Pertinent Information NA Are Particular Training Characteristics Associate with Improved Outcomes? NR

## References

Andersen MR, Yasui Y, Meischke H, et al. The effectiveness of mammography promotion by volunteers in rural communities. Am J Prev Med. Apr. 2000;18(3):199-207. [pmid: 10722985].
Auslander W, Haire-Joshu D, Houston C, et al. A controlled evaluation of staging dietary patterns to reduce the risk of diabetes in African-American women. Diabetes Care. May. 2002;25(5):809-14. [pmid: 11978673].
Williams JH, Belle GA, Houston C, et al. Process evaluation methods of a peer-delivered health promotion program for African American women. Health Promot Pract. April. 1. 2001;2(2):135-42.
Barnes K, Friedman SM, Brickner Namerow P, et al. Impact of community volunteers on immunization rates of children younger than 2 years. Arch Pediatr Adolesc Med. May. 1999;153(5):518-24. [pmid: 10323634].
Barnes-Boyd C, Norr KF, Nacion KW. Promoting infant health through home visiting by a nurse-managed community worker team. Public Health Nursing. 2001 07;18(4):225-35. [pmid: 11468062].
Barth RP, Hacking S, Ash JR. Preventing child abuse: an experimental evaluation of the child parent enrichment project. J Primary Prevent. 1988;8(4):201-17.
Barth RP. An experimental evaluation of in-home child abuse prevention services. Child Abuse Negl. 1991;15(4):363-75. [pmid: 1959070].
Batts ML, Gary TL, Huss K, et al. Patient priorities and needs for diabetes care among urban African American adults. Diabetes Educ. May–Jun. 2001;27(3):405-12. [pmid: 11912801].
Gary TL, Bone LR, Hill MN, et al. Randomized controlled trial of the effects of nurse case manager and community health worker interventions on risk factors for diabetes-related complications in urban African Americans. Prev Med. Jul. 2003;37(1):23-32. [pmid: 12799126].
Vetter MJ, Bristow L, Ahrens J. A model for home care clinician and home health aide collaboration: diabetes care by nurse case managers and community health workers. Home Healthc Nurse. Sep. 2004;22(9):645-8. [pmid: 15359179].
Gary TL, Hill-Briggs F, Batts-Turner M, et al. Translational research principles of an effectiveness trial for diabetes care in an urban African American population. Diabetes Educator. 2005(6):880-9.
Gary TL, Crum RM, Cooper-Patrick L, et al. Depressive symptoms and metabolic control in African-Americans with type 2 diabetes. Diabetes Care. Jan. 2000;23(1):23-9. [pmid: 10857963].
Becker DM, Yanek LR, Johnson WR Jr, et al. Impact of a community-based multiple risk factor intervention on cardiovascular risk in black families with a history of premature coronary disease. Circulation. Mar 15. 2005;111(10):1298-304. [pmid: 15769772].
Cene CW, Yanek LR, Moy TF, et al. Sustainability of a multiple risk factor intervention on cardiovascular disease in high-risk African American families. Ethn Dis. Spring. 2008;18(2):169-75. [pmid: 18507269].
Beckham S, Bradley S, Washburn A, et al. Diabetes management: utilizing community health workers in a Hawaiian/Samoan population. J Health Care Poor Underserved. May. 2008;19(2):416-27. [pmid: 18469413].
Black MM, Dubowitz H, Hutcheson J, et al. A randomized clinical trial of home intervention for children with failure to thrive. Pediatrics. Jun. 1995;95(6):807-14. [pmid: 7539121].
Hutcheson JJ, Black MM, Talley M, et al. Risk status and home intervention among children with failure-to-thrive: follow-up at age 4. J Pediatr Psychol. Oct. 1997;22(5):651-68. [pmid: 9383928].
Bone LR, Mamon J, Levine DM, et al. Emergency department detection and follow-up of high blood pressure: use and effectiveness of community health workers. Am J Emerg Med. Jan. 1989;7(1):16-20. [pmid: 2914043].
Campbell MK, James A, Hudson MA, et al. Improving multiple behaviors for colorectal cancer prevention among African American church members. Health Psychol. Sep. 2004;23(5):492-502. [pmid: 15367069].
Caulfield LE, Gross SM, Bentley ME, et al. WIC-based interventions to promote breastfeeding among African-American women in Baltimore: effects on breastfeeding initiation and continuation. J Hum Lact. Mar. 1998;14(1):15-22. [pmid: 9543954].
Conway TL, Woodruff SI, Edwards CC, et al. Intervention to reduce environmental tobacco smoke exposure in Latino children: null effects on hair biomarkers and parent reports. Tob Control. Mar. 2004;13(1):90-2. [pmid: 14985605].
Corkery E, Palmer C, Foley ME, et al. Effect of a bicultural community health worker on completion of diabetes education in a Hispanic population. Diabetes Care. Mar. 1997;20(3):254-7. [pmid: 9051367].
Derose KP, Fox SA, Reigadas E, et al. Church-based telephone mammography counseling with peer counselors. J Health Commun. Apr–Jun. 2000;5(2):175-88. [pmid: 11010348].
Duan N, Fox SA, Derose KP, et al. Maintaining mammography adherence through telephone counseling in a church-based trial. Am J Public Health. Sep. 2000;90(9):1468-71. [pmid: 10983211].
Derose KP, Hawes-Dawson J, Fox SA, et al. Dealing with diversity: recruiting churches and women for a randomized trial of mammography promotion. Health Educ Behav. Oct. 2000;27(5):632-48. [pmid: 11009131].
Stockdale SE, Keeler E, Duan N, et al. Costs and cost-effectiveness of a church-based intervention to promote mammography screening. Health Serv Res. Dec. 2000;35(5 Pt 1):1037-57. [pmid: 11130802].
Fox SA, Pitkin K, Paul C, et al. Breast cancer screening adherence: does church attendance matter?. Health Educ Behav. Dec. 1998;25(6):742-58. [pmid: 9813745].
Dignan MB, Burhansstipanov L, Hariton J, et al. A comparison of two Native American Navigator formats: face-to-face and telephone. Cancer Control. Nov. 2005;12(Suppl 2):28-33. [pmid: 16327748].
Duggan A, Windham A, McFarlane E, et al. Hawaii's Healthy Start Program of home visiting for at-risk families: evaluation of family identification, family engagement, and service delivery. Pediatrics. Jan. 2000;105(1 Pt 3):250-9. [pmid: 10617732].
Duggan AK, McFarlane EC, Windham AM, et al. Evaluation of Hawaii's Healthy Start Program. Future Child. Spring-Summer. 1999;9(1):66-90. discussion 177–8. [pmid: 10414011].
Earp JA, Eng E, O'Malley MS, et al. Increasing use of mammography among older, rural African American women: results from a community trial. Am J Public Health. Apr. 2002;92(4):646-54. [pmid: 11919066].
Elder JP, Ayala GX, Campbell NR, et al. Long-term effects of a communication intervention for Spanish-dominant Latinas. Am J Prev Med. Aug. 2006;31(2):159-66. [pmid: 16829333].
Elder JP, Ayala GX, Campbell NR, et al. Interpersonal and print nutrition communication for a Spanish-dominant Latino population: Secretos de la Buena Vida. Health Psychol. Jan. 2005;24(1):49-57. [pmid: 15631562].
Erwin DO, Spatz TS, Stotts RC, et al. Increasing mammography practice by African American women. Cancer Pract. Mar–Apr. 1999;7(2):78-85. [pmid: 10352065].
Forst L, Lacey S, Chen HY, et al. Effectiveness of community health workers for promoting use of safety eyewear by Latino farm workers. Am J Ind Med. Dec. 2004;46(6):607-13. [pmid: 15551366].
Frate DA, Johnson SA, Sharpe TR. Solutions to the problems of chronic disease management in rural settings. J Rural Health. Jan. 1985;1(1):52-9. [pmid: 10311750].
Frate DA, Whitehead T, Johnson SA. Selection, training, and utilization of health counselors in the management of high blood pressure. Urban Health. May. 1983;12(5):52-4. [pmid: 10262031].
Gielen AC, McDonald EM, Wilson ME, et al. Effects of improved access to safety counseling, products, and home visits on parents' safety practices: results of a randomized trial. Arch Pediatr Adolesc Med. Jan. 2002;156(1):33-40. [pmid: 11772188].
Graham AV, Frank SH, Zyzanski SJ, et al. A clinical trial to reduce the rate of low birth weight in an inner-city black population. Fam Med. Aug. 1992;24(6):439-46. [pmid: 1397814].
Hiatt RA, Pasick RJ, Stewart S, et al. Cancer screening for underserved women: the Breast and Cervical Cancer Intervention Study. Cancer Epidemiol Biomarkers Prev. Aug. 2008;17(8):1945-9. [pmid: 18708383].
Hunter JB, de Zapien JG, Papenfuss M, et al. The impact of a promotora on increasing routine chronic disease prevention among women aged 40 and older at the U.S.-Mexico border. Health Educ Behav. Aug. 2004;31(4 Suppl):18S-28S. [pmid: 15296689].
Jandorf L, Gutierrez Y, Lopez J, et al. Use of a patient navigator to increase colorectal cancer screening in an urban neighborhood health clinic. J Urban Health. Jun. 2005;82(2):216-24. [pmid: 15888638].
Korfmacher J, O'Brien R, Hiatt S, et al. Differences in program implementation between nurses and paraprofessionals providing home visits during pregnancy and infancy: a randomized trial. Am J Public Health. Dec. 1999;89(12):1847-51. [pmid: 10589314].
Olds DL, Robinson J, O'Brien R, et al. Home visiting by paraprofessionals and by nurses: a randomized, controlled trial. Pediatrics. Sep. 2002;110(3):486-96. [pmid: 12205249].
Olds DL, Robinson J, Pettitt L, et al. Effects of home visits by paraprofessionals and by nurses: age 4 follow-up results of a randomized trial. Pediatrics. Dec. 2004;114(6):1560-8. [pmid: 15574615].
Krieger J, Collier C, Song L, et al. Linking community-based blood pressure measurement to clinical care: a randomized controlled trial of outreach and tracking by community health workers. Am J Public Health. Jun. 1999;89(6):856-61. [pmid: 10358675].
Krieger JK, Takaro TK, Allen C, et al. The Seattle-King County Healthy Homes Project: implementation of a comprehensive approach to improving indoor environmental quality for low-income children with asthma. Environ Health Perspect. Apr. 2002;110(Suppl 2):311-22. [pmid: 11929743].
Krieger JW, Takaro TK, Song L, et al. The Seattle-King County Healthy Homes Project: a randomized, controlled trial of a community health worker intervention to decrease exposure to indoor asthma triggers. Am J Public Health. Apr. 2005;95(4):652-9. [pmid: 15798126].
Levine DM, Bone LR, Hill MN, et al. The effectiveness of a community/academic health center partnership in decreasing the level of blood pressure in an urban African-American population. Ethn Dis. Summer. 2003;13(3):354-61. [pmid: 12894960].
Lujan J, Ostwald SK, Ortiz M. Promotora diabetes intervention for Mexican Americans. Diabetes Educ. Jul–Aug. 2007;33(4):660-70. [pmid: 17684167].
Mock J, McPhee SJ, Nguyen T, et al. Effective lay health worker outreach and media-based education for promoting cervical cancer screening among Vietnamese American women. Am J Public Health. Sep. 2007;97(9):1693-700. [pmid: 17329652].
Morisky DE, Lees NB, Sharif BA, et al. Reducing disparities in hypertension control: a community-based hypertension control project (CHIP) for an ethnically diverse population. Health Promotion Practice. 2002 04;3(2):264-75.
Ward HJ, Morisky DE, Lees NB, et al. A clinic and community-based approach to hypertension control for an underserved minority population: design and methods. Am J Hypertens. Feb. 2000;13(2):177-83. [pmid: 10701818].
Nacion KW, Norr KF, Burnett GM, et al. Validating the safety of nurse-health advocate services. Public Health Nurs. 2000 01;17(1):32-42. [pmid: 10675051].
Navarro AM, Senn KL, McNicholas LJ, et al. Por La Vida model intervention enhances use of cancer screening tests among Latinas. Am J Prev Med. Jul. 1998;15(1):32-41. [pmid: 9651636].
Navarro AM, Senn KL, Kaplan RM, et al. Por La Vida intervention model for cancer prevention in Latinas. J Natl Cancer Inst Monogr. 1995(18):137-45.
Navarro AM, McNicholas LJ, Senn KL, et al. Use of cancer screening tests among Latinas one and two years after participation in the Por La Vida Damos Cuenta program. J Women's Cancer. 2000;2(1):23-30.
Parker EA, Israel BA, Robins TG, et al. Evaluation of Community Action Against Asthma: a community health worker intervention to improve children's asthma-related health by reducing household environmental triggers for asthma. Health Educ Behav. Jun. 2008;35(3):376-95. [pmid: 17761540].
Paskett E, Tatum C, Rushing J, et al. Randomized trial of an intervention to improve mammography utilization among a triracial rural population of women. J Natl Cancer Inst. Sep 6. 2006;98(17):1226-37. [pmid: 16954475].
Katz ML, Tatum CM, Degraffinreid CR, et al. Do cervical cancer screening rates increase in association with an intervention designed to increase mammography usage?. J Womens Health (Larchmt). Jan–Feb. 2007;16(1):24-35. [pmid: 17324094].
Pilote L, Tulsky JP, Zolopa AR, et al. Tuberculosis prophylaxis in the homeless. A trial to improve adherence to referral. Arch Intern Med. Jan 22. 1996;156(2):161-5. [pmid: 8546549].
Rask KJ, LeBaron CW, Starnes DM. The costs of registry-based immunization interventions. Am J Prev Med. Nov. 2001;21(4):267-71. [pmid: 11701296].
LeBaron CW, Starnes DM, Rask KJ. The impact of reminder-recall interventions on low vaccination coverage in an inner-city population. Arch Pediatr Adolesc Med. Mar. 2004;158(3):255-61. [pmid: 14993085].
Sauaia A, Min SJ, Lack D, et al. Church-based breast cancer screening education: impact of two approaches on Latinas enrolled in public and private health insurance plans. Prev Chronic Dis. Oct. 2007;4(4):A99. [pmid: 17875274].
Welsh AL, Sauaia A, Jacobellis J, et al. The effect of two church-based interventions on breast cancer screening rates among Medicaid-insured Latinas. Prev Chronic Dis. Oct. 2005;2(4):A07.
Schuler ME, Nair P, Black MM, et al. Mother-infant interaction: effects of a home intervention and ongoing maternal drug use. J Clin Child Psychol. Sep. 2000;29(3):424-31. [pmid: 10969426].
Schwarz DF, Grisso JA, Miles C, et al. An injury prevention program in an urban African-American community. Am J Public Health. May. 1993;83(5):675-80. [pmid: 8484447].
Silver EJ, Ireys HT, Bauman LJ, et al. Psychological outcomes of a support intervention in mothers of children with ongoing health conditions: the parent-to-parent network. J Commun Psychol. 1997;25(3):249-64.
St James PS, Shapiro E, Waisbren SE. The Resource Mothers Program for Maternal Phenylketonuria. Am J Public Health. May. 1999;89(5):762-4. [pmid: 10224992].
Sung JF, Blumenthal DS, Coates RJ, et al. Effect of a cancer screening intervention conducted by lay health workers among inner-city women. Am J Prev Med. Jan–Feb. 1997;13(1):51-7.
Sung JF, Coates RJ, Williams JE, et al. Cancer screening intervention among black women in inner-city Atlanta--design of a study. Public Health Rep. Jul–Aug. 1992;107(4):381-8. [pmid: 1641433].
Taylor VM, Hislop TG, Jackson JC, et al. A randomized controlled trial of interventions to promote cervical cancer screening among Chinese women in North America. J Natl Cancer Inst. May 1. 2002;94(9):670-7. [pmid: 11983755].
Tessaro I, Campbell M, O'Meara C, et al. State health department and university evaluation of North Carolina's Maternal Outreach Worker Program. Am J Prev Med. Nov–Dec. 1997;13(6 Suppl):38-44. [pmid: 9455592].
Navaie-Waliser M, Martin SL, Tessaro I, et al. Social support and psychological functioning among high-risk mothers: the impact of the Baby Love Maternal Outreach Worker Program. Public Health Nurs. Jul–Aug. 2000;17(4):280-91. [pmid: 10943776].
Von Korff M, Moore JE, Lorig K, et al. A randomized trial of a lay person-led self-management group intervention for back pain patients in primary care. Spine. Dec 1. 1998;23(23):2608-15. [pmid: 9854760].
Wendell DA, Cohen DA, LeSage D, et al. Street outreach for HIV prevention: effectiveness of a state-wide programme. Int J STD AIDS. May. 2003;14(5):334-40. [pmid: 12803941].
Wilson TE, Fraser-White M, Feldman J, et al. Hair salon stylists as breast cancer prevention lay health advisors for African American and Afro-Caribbean women. J Health Care Poor Underserved. Feb. 2008;19(1):216-26. [pmid: 18263997].
Wolff N, Helminiak TW, Morse GA, et al. Cost-effectiveness evaluation of three approaches to case management for homeless mentally ill clients. Am J Psychiatry. Mar. 1997;154(3):341-8. [pmid: 9054781].
Morse GA, Calsyn RJ, Klinkenberg WD, et al. An experimental comparison of three types of case management for homeless mentally ill persons. Psychiatr Serv. Apr. 1997;48(4):497-503. [pmid: 9090733].
Balcazar H, Alvarado M, Hollen ML, et al. Salud Para Su Corazon-NCLR: a comprehensive promotora outreach program to promote heart-healthy behaviors among Hispanics. Health Promot Pract. Jan. 2006;7(1):68-77. [pmid: 16410422].
Beck B, Young S, Ahmed S, et al. Development of a church-based cancer education curriculum using CBPR. J Health Care Poor Underserved. Feb. 2007;18(1):28-34. [pmid: 17337794].
Bell RA, Hillers VN, Thomas TA. The Abuela Project: safe cheese workshops to reduce the incidence of Salmonella typhimurium from consumption of raw-milk fresh cheese. Am J Public Health. Sep. 1999;89(9):1421-4. [pmid: 10474564].
Kuhajda MC, Cornell CE, Brownstein JN, et al. Training community health workers to reduce health disparities in Alabama's Black Belt: the Pine Apple Heart Disease and Stroke Project. Fam Community Health. Apr–Jun. 2006;29(2):89-102. [pmid: 16552287].
Martinez-Bristow Z, Sias JJ, Urquidi UJ, et al. Tobacco cessation services through community health workers for Spanish-speaking populations. Am J Public Health. Feb. 2006;96(2):211-3. [pmid: 16380561].
Navarro AM, Raman R, McNicholas LJ, et al. Diffusion of cancer education information through a Latino community health advisor program. Prev Med. Aug–Sep. 2007;45(2–3):135-8. [pmid: 17604831].
Navarro AM, McNicholas LJ, Cruz M, et al. Development and implementation of a curriculum on cancer screening for small groups of Latino women. J Cancer Educat. 2007;22(3):186-90.
Perez M, Findley SE, Mejia M, et al. The impact of community health worker training and programs in NYC. J Health Care Poor Underserved. Feb. 2006;17(1 Suppl):26-43. [pmid: 16520505].
Williams MP. Increasing participation in health promotion among older African-Americans. Am J Health Behav. 1996;11;20(6):389.
Yu MY, Song L, Seetoo A, et al. Culturally competent training program: a key to training lay health advisors for promoting breast cancer screening. Health Educ Behav. Dec. 2007;34(6):928-41. [pmid: 17965228].