# Abstract Forms

Abstract Review Form (Originally in Excel)

Column | Question
A | Refid
B | Author, Year
C | Original research (Exclude editorials, commentaries, letters to the editor, reviews etc)
D | Includes community health worker component
E | Study published in English?
F | Is this study located in the US?
G | If not in US, where?
H | RCT and n ≥ 40
I | Cohorts with comparison and n ≥ 40
J | Cost or cost-benefit analysis
K | Exclude (“No” on one or more questions in Columns C - I)?
L | Name of intervention (if provided)
M | Retain for - Background or discussion or review of references other….
N | Comments
O | Reviewer initials

Full-text review form (Originally in EXCEL)

Column | Question
A | Refid
B | Author, year
C | Reviewer Initials
D | Abstract only
E | Wrong population (non-US)
F | Wrong Outcomes (no patient related health or economic outcomes)
G | Study not about CHW
H | Wrong publication type (review or letter to the editor)
I | Sample size too small (<40)
J | No comparison arm/data
K | Comparison arm/data not about CHW or CHW alone
L | CHW component insufficiently described to distinguish between CHW and other peer led models
M | Other?
N | Exclude but save for background, cost, training or setting, pick one! (only if yes for at least one column D-M)
O | Should be included for KQ 4a (What are characteristics of training for community health workers in the outpatient setting?)
P | Should be included!
Q | Need more information
R | Related citations
S | Left blank
T | How do community health workers interact with clients? Specifically, what is the place of service, type of service, type of educational materials used, duration of interaction with clients, and length of followup?
U | What is the impact of community health workers on outcomes, particularly knowledge, behavior, satisfaction, health outcomes, and health care utilization?
V | What is known about the cost-effectiveness of community health workers for improving health outcomes?
W | Are particular training characteristics associated with improved outcomes for patients?
X | Study design
Y | Comparisons (identify arms)
Z | Health condition of interest
AA | Name of intervention
AB | Notes- including additional citations

Abstraction Form for Evidence Tables (Originally in EXCEL)

Column | Category | Question
A | Identifying information | Reviewer Initials
B | Identifying information | Author Year {#RefID}
C | Identifying information | Trial Name
D | Identifying information | Objective or aim
E | Setting | Setting: Geography
F | Setting | Setting: Organizational, Social, Cultural
G | Setting | What is the community? (neighborhood, disease etc.)
H | Setting | Study design: RCT/Prospective cohort/Retropective cohort/Prospective cohort with historic control/case- control/case series/other
I | Setting | Start date- year
J | Setting | Duration - length
K | N | Eligible
L | N | Enrolled
M | N | Randomized
N | N | Completers
O | N | Withdrawals or dropouts
P | | Health condition of interest
Q | Inclusion/Exclusion | Inclusion criteria (include run-in details)
R | Inclusion/Exclusion | Exclusion criteria
S | Groups | Groups (please use- G1: G2: G3: etc.)
T | Groups | Describe interventions (if necessary)
U | Groups | n of each group
V | Community Health Worker | CHW definition:
W | Community Health Worker | CHW training:
X | Community Health Worker | Place of service
Y | Community Health Worker | Title of CHW (specify: lay health advisor, community health worker, etc)
Z | Community Health Worker | Paid or volunteer
AA | Community Health Worker | Relationship with the community (rshared race, ethnicity, disease condition, etc)
AB | Community Health Worker | N of CHW
AC | Community Health Worker | Supervision of CHW (who supervises [clinician vs non clinician] and frequency of supervision)
ad | Community Health Worker | Prior training of CHW
AE | Community Health Worker | Type of service
AF | Community Health Worker | Type of educational materials utilized
AG | Community Health Worker | Duration of interaction with clients
AH | Community Health Worker | Length of followup
AI | Baseline characteristics of patients | Age (mean)
AJ | Baseline characteristics of patients | Sex (% female)
AK | Baseline characteristics of patients | Race (%)
AL | Baseline characteristics of patients | Other?
AM | Recruiting and retention | Role of CHW in recruiting and retention
AN | Recruiting and retention | Recruitment: Need rates for each group
AO | Recruiting and retention | Retention: Need rates for each group
AP | Knowledge and attitude | Measure (Is it valdidated?)
AQ | Knowledge and attitude | Results
AR | Knowledge and attitude | Measure (Is it valdidated?)
AS | Knowledge and attitude | Results
AT | Knowledge and attitude | Measure (Is it valdidated?)
AU | Knowledge and attitude | Results
AV | Quality of Life | Measure (Is it valdidated?)
AW | Quality of Life | Results
AX | Quality of Life | Measure (Is it valdidated?)
AY | Quality of Life | Results
AZ | Quality of Life | Measure (Is it valdidated?)
BA | Quality of Life | Results
BB | Health Outcomes | Measure (Is it valdidated?)
BC | Health Outcomes | Results
BD | Health Outcomes | Measure (Is it valdidated?)
BE | Health Outcomes | Results
BF | Health Outcomes | Measure (Is it valdidated?)
BG | Health Outcomes | Results
BH | Healthcare utilization | Measure (Is it valdidated?)
BI | Healthcare utilization | Results
BJ | Healthcare utilization | Measure (Is it valdidated?)
BK | Healthcare utilization | Results
BL | Healthcare utilization | Measure (Is it valdidated?)
BM | Healthcare utilization | Results
BN | Costs (Economics) | Measure (Is it valdidated?)
BO | Costs (Economics) | Results
BP | Costs (Economics) | Measure (Is it valdidated?)
BQ | Costs (Economics) | Results
BR | | Explanation of overall outcomes.
BS | | Quality rating: Good/fair/poor
BT | Applicable key questions | KQ 1 - How do community health workers interact with clients? Specifically, what is the place of service, type of service, type of educational materials used, duration of interaction with clients, and length of followup?
BU | Applicable key questions | KQ 2 - What is the impact of community health workers on outcomes, particularly knowledge, behavior, satisfaction, health outcomes, and health care utilization?
BV | Applicable key questions | KQ 3 - What is known about the cost-effectiveness of community health workers for improving health outcomes?
BW | Applicable key questions | KQ 4a - What are characteristics of training for community health workers in the outpatient setting?
BX | Applicable key questions | KQ 4b - Are particular training characteristics associated with improved outcomes for patients?
BY | Additional outcomes (please add more here at the end if you must!) | Measure (Is it validated?)
BZ | Additional outcomes (please add more here at the end if you must!) | Results
CA | Additional outcomes (please add more here at the end if you must!) | Measure (Is it validated?)
CB | Additional outcomes (please add more here at the end if you must!) | Results
CC | Additional outcomes (please add more here at the end if you must!) | Measure (Is it validated?)
CD | Additional outcomes (please add more here at the end if you must!) | Results
CE | Additional outcomes (please add more here at the end if you must!) | Measure (Is it validated?)
CF | Additional outcomes (please add more here at the end if you must!) | Results
CG | | The gulf between the rest and KQ4a
CH | | (Blank)
CI | Training Characteristics | Eligibility for CHW training (inclusion criteria for CHW)
CJ | Training Characteristics | Input of CHW in curriculum development
CK | Training Characteristics | Training on cultural competency (describe content; instructional method; number of sessions; testing)
CL | Training Characteristics | Training on recruitment and retention process skills, e.g., motivational interviewing (describe content; instructional method; number of sessions; testing)
CM | Training Characteristics | Training on intake/assessment, (describe content; instructional method; number of sessions; testing)
CN | Training Characteristics | Training on protocol delivery, i.e., recruitment, followup, fidelity to the intervention, referrals (describe content; instructional method; number of sessions; testing)
CO | Training Characteristics | Training on health topic (describe content; instructional method; number of sessions; testing)
CP | Training Characteristics | Training on evaluation (describe content; instructional method; number of sessions; testing)
CQ | Training Characteristics | Other training (describe type)
CR | Training Characteristics | Other training content; instructional method; number of sessions; testing
CS | Training Characteristics | Other training (describe type)
CT | Training Characteristics | Other training content; instructional method; number of sessions; testing
CU | Training Characteristics | Name of curriculum
CV | Training Characteristics | Availability
CW | Training Characteristics | Evaluation and testing results of the curriculum (improvements in CHW knowledge)
CX | Training Characteristics | Certification (any certication [yes/no/nr]; if yes, name of certifying body

Quality Review for randomized controlled trials (Originally in EXCEL)

Column | Category | Question
A | | REFID
B | | Reviewer initial
C | Background/context | Is the hypothesis/aim/objective of the study described? Yes No
D | Sample Definition and Selection | Are the inclusion/exclusion criteria clearly stated (does not require the reader to infer)? [Abstractor: use “Partially” if only some criteria are stated clearly.] Yes Partially No
E | Sample Definition and Selection | Did the authors report conducting a power analysis or some other basis for determining the adequacy of study group sizes for the primary outcome(s) being abstracted? Yes No
F | Randomization | Was the assignment to the treatment groups adequately randomized? Yes (Adequate approaches to sequence generation, i.e., computer-generated random numbers, random numbers tables) No (Inadequate approaches to sequence generation, i.e., use of alternation, case record numbers, birth dates or week days) NR
G | Randomization | Was allocation of randomization adequately concealed? Yes (Adequate approaches to concealment of randomisation, i.e., centralised or pharmacy-controlled randomisation, serially- numbered identical containers, on-site computer based system with a randomisation sequence that is not readable until allocation, other approaches with robust methods to prevent foreknowledge of the allocation sequence to clinicians and patients) No (Inadequate approaches to concealment of randomisation, i.e., use of alternation, case record numbers, birth dates or week days, open random numbers lists, serially numbered envelopes (even sealed opaque envelopes can be subject to manipulation) NA (study not adequately randomized) NR
H | Interventions/Exposure | What is the level of detail in describing the intervention or exposure? Low (unclear, many details missing) Medium (pretty clear, most details provided) High (very clear, all required details provided)
I | Interventions/Exposure | Is usual clinical care (sometimes called standard care) described? Yes No NA (not an intervention study)
J | Contamination | Did researchers rule out any impact from an unintended intervention/exposure that might bias results, e.g., through multivariate analysis, stratification, or subgroup analysis? Yes No NA (no unintended interventions reported)
K | Contamination | Could variation from the protocol have compromised the findings of study? Yes (variation from protocol exists and could have compromised findings) No (variation from protocol exists, but unlikely to have compromised findings) Cannot determine (no variation from protocol reported) NA (study does not require protocol, or no variation from protocol exists)
L | Blinding | Outcome assessors masked? Yes No Yes, but method not described Not reported
M | Blinding | Care provider masked? Yes No Yes, but method not described Not reported NA
N | Blinding | Patient masked? Yes No Yes, but method not described Not reported
O | Soundness of information | Are interventions/exposures measured in a valid and reliable manner? Objective (clinical reports, lab findings, previously validated measures) Objective measure, not validated Prospective documentation (including self-report in daily diaries) Retrospective self-report (patient/participant response) Not reported
P | Soundness of information | Are outcomes measured in a valid and reliable manner? Objective (clinical reports, lab findings, previously validated measures) Objective measure, not validated Prospective documentation (including self-report in daily diaries) Retrospective self-report (patient/participant response) Not reported
Q | Follow-up | Is the length of time following the intervention/exposure sufficient to support the conclusions of the study regarding outcomes? Yes No
R | Follow-up | Did attrition from any group exceed 20 percent (after randomization)? Yes - how much? No Cannot determine
S | Follow-up | Did attrition differ between groups by more than 15 percentage points (after randomization)? Yes - how much? No Cannot determine
T | Analysis Comparability | Are baseline characteristics similar in exposed and comparison cohorts? Yes No Cannot determine
U | Analysis Comparability | Does the analysis control for baseline differences? Yes No Cannot determine NA (no baseline differences reported)
V | Analysis Outcome | Is the analysis conducted on an intention-to-treat (ITT) basis, that is, the intervention allocation status rather than the actual intervention received? Yes No
W | Analysis Outcome | Were there any post-randomization exclusions? Yes (how many?) No Cannot tell
X | Interpretation | Are conclusions supported by results with possible bias and limitations taken into consideration? Yes Partially No
Y | Quality | Good Fair Poor

Quality Review for observational trials (Originally in EXCEL)

Column | Category | Question
A | | REFID
B | | Reviewer initial
C | Background/Context | Is the hypothesis/aim/objective of the study described? Yes No
D | Sample Definition and Selection | Are the inclusion/exclusion criteria clearly stated (does not require the reader to infer)? [Abstractor: use “Partially” if only some criteria are stated clearly.] Yes Partially No
E | Sample Definition and Selection | Did the authors report conducting a power analysis or some other basis for determining the adequacy of study group sizes for the primary outcome(s) being abstracted? Yes No
F | Interventions/Exposure | What is the level of detail in describing the intervention or exposure? Intensity, duration, frequency, setting and timing Low (unclear, many details missing) Medium (pretty clear, most details provided) High (very clear, all required details provided)
G | Interventions/Exposure | Is usual clinical care (sometimes called standard care) described? Yes No NA (not an intervention study)
H | Contamination | Did researchers rule out any impact from an unintended intervention/exposure that might bias results, e.g., through multivariate analysis, stratification, or subgroup analysis? Yes No NA (no unintended interventions reported)
I | Contamination | Could variation from the protocol have compromised the findings of study? Yes (variation from protocol exists and could have compromised findings) No (variation from protocol exists, but unlikely to have compromised findings) Cannot determine (no variation from protocol reported) NA (study does not require protocol, or no variation from protocol exists)
J | Blinding | Were the outcome assessors blinded to the intervention or exposure status of participants? Yes No NA (not an intervention study)
K | Soundness of information | Are interventions/exposures measured in a valid and reliable manner? Objective (clinical reports, lab findings, previously validated measures) Objective measure, not validated Prospective documentation (including self-report in daily diaries) Retrospective self-report (patient/participant response) Not reported
L | Soundness of information | Are outcomes measured in a valid and reliable manner? Objective (clinical reports, lab findings, previously validated measures) Objective measure, not validated Prospective documentation (including self-report in daily diaries) Retrospective self-report (patient/participant response) Not reported
M | Follow-up | In cohort studies, do the analyses adjust for different lengths of follow-up of patients, or in case-control studies, is the time period between the intervention/exposure and outcome the same for cases and controls? [Abstractor: Where follow-up was the same for all study patients the answer is yes. If different lengths of follow-up were adjusted by, for example, survival analysis, the answer is yes. Studies where differences in follow-up are ignored should be answered NA.] Yes No Cannot determine NA (cross-sectional)
N | Follow-up | Is the length of time following the intervention/exposure sufficient to support the conclusions of the study regarding outcomes? Yes No NA (cross-sectional)
O | Follow-up | Did attrition from any group exceed 20 percent (after allocation of treatment)? Yes - how much? No Cannot determine NA (cross sectional)
P | Follow-up | Did attrition differ between groups by more than 15 percentage points (after allocation of treatment)? Yes - how much? No Cannot determine NA (cross sectional)
Q | Analysis comparability | Are baseline characteristics similar in exposed and comparison cohorts? Yes No Cannot determine NA (case series)
R | Analysis comparability | Does the analysis control for baseline differences? Yes No Cannot determine NA (no baseline differences reported)
S | Analysis comparability | Were the important confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? Yes Partially No Cannot determine
T | Analysis Outcome | Is the analysis conducted on an intention-to-treat (ITT) basis, that is, the intervention allocation status rather than the actual intervention received? Yes No
U | Analysis Outcome | Is the impact of loss to follow-up (or differential loss to followup) assessed (e.g. through sensitivity analysis or other intention-to- treat adjustment methods? Yes No Cannot determine NA (cross-sectional or case-control selected on outcome)
V | Analysis Outcome | Are the statistical methods used to assess the primary outcomes appropriate to the data? [Abstractor: The statistical techniques used must be appropriate to the data. For example, non-parametric methods should be used for small sample sizes (N<30). If studies have not accounted for differences between the unit of allocation and the unit of analysis, (e.g., through mixed models or generalized estimating equations for analysis of individual covariates or through t-tests or weighted t-tests for cluster-level analysis) then the answer is no. If outcomes are rare and little or no statistical analysis has been conducted, answer yes if studies have accounted for alternative causes other than the intervention/exposure. For details on whether specific statistical tests are appropriate, go to http://bama.ua.edu/~jleeper/627/choosestat.html.4] Yes Partially No NA (not reported)
W | Analysis Outcome | For cohort studies only, if the outcome has a greater than 10 percent prevalence, is the risk ratio and relative risk calculated directly (not using logistic regression)? Yes No NA (not a cohort study)
X | Analysis Outcome | Does the study report appropriate estimates of the random variability in the data for the main outcomes?4 [Abstractors: In non- normally distributed data the inter-quartile range of results should be reported. In normally distributed data the standard error, standard deviation or confidence intervals should be reported.] Yes No
Y | Interpretation | Are conclusions supported by results with possible bias and limitations taken into consideration? Yes Partially No
Z | Quality | Good Fair Poor