# Exact Search Strings

Medline Focused Search: April 2008

#2 | Search “Community Health Aides”[Mesh] OR “health advisor” OR “health worker” OR “health advocate” OR “health paraprofessional” OR “community health representative” OR “outreach worker” OR dumas OR promotoras OR embajadores OR consejeras | 6051
#3 | Search “Community Health Aides”[Mesh] OR “health advisor” OR “health worker” OR “health advocate” OR “health paraprofessional” OR “community health representative” OR “outreach worker” OR dumas OR promotoras OR embajadores OR consejeras Limits: Humans, English | 3031
#6 | Search ((“Outcome Assessment (Health Care)”[Mesh] OR “Pregnancy Outcome”[Mesh])) OR (“Treatment Outcome”[Mesh] OR “Outcome and Process Assessment (Health Care)”[Mesh] OR “Fatal Outcome”[Mesh]) Limits: Humans, English | 369350
#7 | Search #3 AND #6 Limits: Humans, English | 175
#17 | Search (((“Patient Education as Topic”[Mesh] OR “Patient Education Handout “[Publication Type])) OR “Professional-Patient Relations”[Mesh]) OR “Office Visits”[Mesh] Limits: Humans, English | 109582
#18 | Search #3 AND #17 Limits: Humans, English | 90
#26 | Search (“Costs and Cost Analysis”[Mesh] OR “Economics”[Mesh] OR “economics “[Subheading] OR “Cost-Benefit Analysis”[Mesh] OR “Cost Allocation”[Mesh] OR “Cost of Illness”[Mesh] OR “Cost Control”[Mesh] OR “Cost Sharing”[Mesh] OR “Cost Savings”[Mesh] OR “Health Care Costs”[Mesh] OR “Direct Service Costs”[Mesh] OR “Hospital Costs”[Mesh] OR “Employer Health Costs”[Mesh] OR “Drug Costs”[Mesh]) Limits: Humans, English | 257114
#27 | Search #3 AND #26 Limits: Humans, English | 254
#28 | Search United States Limits: Humans, English | 606881
#29 | Search #27 AND #28 Limits: Humans, English | 71
#33 | Search ((“Education”[Mesh] OR “education “[Subheading])) OR “Education, Professional”[Mesh] OR training Limits: Humans, English | 370579
#34 | Search #3 AND #33 Limits: Humans, English | 1013
#35 | Search #34 AND #28 Limits: Humans, English | 241
#41 | Search ((((“Randomized Controlled Trials as Topic”[Mesh] OR “Randomized Controlled Trial “[Publication Type])) OR “Single-Blind Method”[Mesh]) OR “Double-Blind Method”[Mesh]) OR “Random Allocation”[Mesh] Limits: Humans, English | 303728
#42 | Search #3 AND #41 Limits: Humans, English | 165
#44 | Search control OR controlled Limits: Humans, English | 1368901
#45 | Search #3 AND #44 Limits: Humans, English | 908
#46 | Search #45 AND #28 Limits: Humans, English | 154

Medline unduplicated records = 640

Cochrane April 2008

Analogous terms = 11*

*Unduplicated in Medline search

Cochrane Clinical Trials Registry April 2008

Analogous terms = 41*

Unduplicated in Medline search

CINAHL April 2008

Analogous terms

KQ1 = 61*

KQ2 = 45*

KQ3 = 21*

KQ4 = 21*

*Unduplicated in Medline search

Total unduplicated across all searches = 815

Update search November 2008

Medline = 38*

Cochrane = 0

Cochrane Clinical Trials Registry = 9*

CINAHL = 13*

*Unduplicated in previous searches

Supplemental search: “Patient Navigator”

Medline = 21

CINAHL = 26

Cochrane – 8

Total new (unduplicated across all new and prior searches) = 25