# Appendixes

Appendix A Exact Search Strings

Appendix B Abstract Forms

Appendix C Evidence Tables

Appendix D Excluded Studies

Appendix E Acknowledgments