# References

1 Silverstein MD, Heit JA, Mohr DN, Petterson TM, O'Fallon WM, Melton LJ 3rd. Trends in the incidence of deep vein thrombosis and pulmonary embolism: a 25-year population-based study. Arch Intern Med. 1998;158(6):585-93. [pmid: 9521222].
2 White RH. The epidemiology of venous thromboembolism. Circulation. 2003;107(23 Suppl 1):I4-8. [pmid: 12814979].
3 Seligsohn U, Lubetsky A. Genetic susceptibility to venous thrombosis. N Engl J Med. 2001;344(16):1222-31. [pmid: 11309638].
4 Eldor A. The use of low-molecular-weight heparin for the management of venous thromboembolism in pregnancy. Eur J Obstet Gynecol Reprod Biol. 2002;104(1):3-13. [pmid: 12128275].
5 Warkentin TE. Heparin-induced thrombocytopenia: a clinicopathologic syndrome. Thromb Haemost. 1999;82(2):439-47. [pmid: 10605735].
6 Welch GN, Loscalzo J. Homocysteine and atherothrombosis. N Engl J Med. 1998;338(15):1042-50. [pmid: 9535670].
7 Khajuria A, Houston DS. Induction of monocyte tissue factor expression by homocysteine: a possible mechanism for thrombosis. Blood. 2000;96(3):966-72. [pmid: 10910911].
8 Undas A, Williams EB, Butenas S, Orfeo T, Mann KG. Homocysteine inhibits inactivation of factor Va by activated protein C. J Biol Chem. 2001;276(6):4389-97. [pmid: 11083858].
9 Stein PD, Hull RD, Kayali F, Ghali WA, Alshab AK, Olson RE. Venous thromboembolism according to age: the impact of an aging population. Arch Intern Med. 2004;164(20):2260-5. [pmid: 15534164].
10 Crowther MA, Roberts J, Roberts R, et al. Fibrinolytic variables in patients with recurrent venous thrombosis: a prospective cohort study. Thromb Haemost. 2001;85(3):390-4. [pmid: 11307802].
11 Koster T, Rosendaal FR, Briet E, Vandenbroucke JP. John Hageman's factor and deep-vein thrombosis: Leiden thrombophilia Study. Br J Haematol. 1994;87(2):422-4. [pmid: 7947293].
12 Ridker PM, Vaughan DE, Stampfer MJ, et al. Baseline fibrinolytic state and the risk of future venous thrombosis. A prospective study of endogenous tissue-type plasminogen activator and plasminogen activator inhibitor. Circulation. 1992;85(5):1822-7. [pmid: 1572039].
13 Roberts HR, Stinchcombe TE, Gabriel DA. The dysfibrinogenaemias. Br J Haematol. 2001;114(2):249-57. [pmid: 11529842].
14 Kyrle PA, Minar E, Bialonczyk C, Hirschl M, Weltermann A, Eichinger S. The risk of recurrent venous thromboembolism in men and women. N Engl J Med. 2004;350(25):2558-63. [pmid: 15201412].
15 Hansson PO, Sorbo J, Eriksson H. Recurrent venous thromboembolism after deep vein thrombosis: incidence and risk factors. Arch Intern Med. 2000;160(6):769-74. [pmid: 10737276].
16 Heit JA, Mohr DN, Silverstein MD, Petterson TM, O'Fallon WM, Melton LJ 3rd. Predictors of recurrence after deep vein thrombosis and pulmonary embolism: a population-based cohort study. Arch Intern Med. 2000;160(6):761-8. [pmid: 10737275].
17 Kearon C, Ginsberg JS, Kovacs MJ, et al. Comparison of low-intensity warfarin therapy with conventional-intensity warfarin therapy for long-term prevention of recurrent venous thromboembolism. N Engl J Med. 2003;349(7):631-9. [pmid: 12917299].
18 Lee AY, Levine MN, Baker RI, et al. Low-molecular-weight heparin versus a coumarin for the prevention of recurrent venous thromboembolism in patients with cancer. N Engl J Med. 2003;349(2):146-53. [pmid: 12853587].
19 Palareti G, Legnani C, Cosmi B, et al. Predictive value of D-dimer test for recurrent venous thromboembolism after anticoagulation withdrawal in subjects with a previous idiopathic event and in carriers of congenital thrombophilia. Circulation. 2003;108(3):313-8. [pmid: 12847064].
20 Prandoni P, Lensing AW, Prins MH, et al. Residual venous thrombosis as a predictive factor of recurrent venous thromboembolism. Ann Intern Med. 2002;137(12):955-60. [pmid: 12484710].
21 Kujovich JL. Factor V Leiden Thrombophilia. GeneReview on GeneTests. .Last Updated 5/20/04.
22 Spector EB, Grody WW, Matteson CJ, et al. Technical standards and guidelines: venous thromboembolism (Factor V Leiden and prothrombin 20210G >A testing): a disease-specific supplement to the standards and guidelines for clinical genetics laboratories. Genet Med. 2005;7(6):444-53. [pmid: 16024978].
23 Ridker PM, Miletich JP, Hennekens CH, Buring JE. Ethnic distribution of factor V Leiden in 4047 men and women. Implications for venous thromboembolism screening. JAMA. 1997;277(16):1305-7. [pmid: 9109469].
24 Chang MH, Lindegren ML, Butler MA, et al. Prevalence in the United States of selected candidate gene variants: Third National Health and Nutrition Examination Survey, 1991–1994. Am J Epidemiol. 2009;169(1):54-66. [pmid: 18936436].
25 Emmerich J, Rosendaal FR, Cattaneo M, et al. Combined effect of factor V Leiden and prothrombin 20210A on the risk of venous thromboembolism--pooled analysis of 8 case-control studies including 2310 cases and 3204 controls. Study Group for Pooled-Analysis in Venous Thromboembolism. Thromb Haemost. 2001;86(3):809-16. [pmid: 11583312].
26 Martinelli I, Bucciarelli P, Margaglione M, De Stefano V, Castaman G, Mannucci PM. The risk of venous thromboembolism in family members with mutations in the genes of factor V or prothrombin or both. Br J Haematol. 2000;111(4):1223-9. [pmid: 11167765].
27 http:www.fda.gov/cdrh/pdf6/K060564.pdf.
28 http:www.fda.gov/cdrh/pdf3/k033612.pdf.
29 Sanderson S, Zimmern R, Kroese M, Higgins J, Patch C, Emery J. How can the evaluation of genetic tests be enhanced? Lessons learned from the ACCE framework and evaluating genetic tests in the United Kingdom. Genet Med. 2005;7(7):495-500. [pmid: 16170241].
30 Berlin JA. Does blinding of readers affect the results of meta-analyses? University of Pennsylvania Meta-analysis Blinding Study Group. Lancet. 1997;350(9072):185-6. [pmid: 9250191].
31 Bossuyt PM, Reitsma JB, Bruns DE, et al. Towards complete and accurate reporting of studies of diagnostic accuracy: the STARD initiative. Fam Pract. 2004;21(1):4-10. [pmid: 14760036].
32 Segal J, Strouse J, Beach M, et al. Hydroxyurea for the Treatment of Sickle Cell Disease. . Evidence Report/Technology Assessment No. 165. (Prepared by Johns Hopkins University Evidence-Based Practice Center Under Contract No. 290-02-0018). AHRQ Publication No. 08-E007. Rockville, MD. Agency for Healthcare Research and Quality. 2008.
33 Marchionni L, Wilson R, Marinopoulos S, et al. Impact of Gene Expression Profiling Tests on Breast Cancer Outcomes. Evidence Report/Technology Assessment No. 160. (Prepared by The Johns Hopkins University Evidence-Based Practice Center Under Contract No. 290-02-0018). AHRQ Publication No. 08-E002. Rockville, MD. Agency for Healthcare Research and Quality. 2008.
34 The Joanna Briggs Institute. Appraisal, extraction and pooling of evidence arising out of qualitative research. Accessed December 01, 2008. from www.joannabriggs.edu.au/cqrmg/documents/QARI_CQRMG.pps.
35 Philips Z, Ginnelly L, Sculpher M, et al. Review of guidelines for good practice in decision-analytic modelling in health technology assessment. Health Technol Assess. 2004;8(36):iii-iv, ix-xi, 1-158.
36 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
37 Higgins JP, Thompson SG, Deeks JJ, Altman DG. Measuring inconsistency in meta-analyses. BMJ. 2003;327(7414):557-60. [pmid: 12958120].
38 Duval S, Tweedie R. Trim and fill: A simple funnel-plot-based method of testing and adjusting for publication bias in meta-analysis. Biometrics. 2000;56(2):455-63. [pmid: 10877304].
39 Egger M, Davey Smith G, Schneider M, Minder C. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315(7109):629-34. [pmid: 9310563].
40 Atkins D, Best D, Briss PA, et al. Grading quality of evidence and strength of recommendations. BMJ. 2004;328(7454):1490. [pmid: 15205295].
41 Teutsch SM, Bradley LA, Palomaki GE, et al. The Evaluation of Genomic Applications in Practice and Prevention (EGAPP) initiative: methods of the EGAPP Working Group. Genet Med. 2008.
42 Coppens M, van de Poel MH, Bank I, et al. A prospective cohort study on the absolute incidence of venous thromboembolism and arterial cardiovascular disease in asymptomatic carriers of the prothrombin 20210A mutation. Blood. 2006;108(8):2604-7. [pmid: 16778142].
43 Hessner MJ, Budish MA, Friedman KD. Genotyping of factor V G1691A (Leiden) without the use of PCR by invasive cleavage of oligonucleotide probes. Clin Chem. 2000;46(8 Pt 1):1051-6. [pmid: 10926882].
44 Ledford M, Friedman KD, Hessner MJ, Moehlenkamp C, Williams TM, Larson RS. A multi-site study for detection of the factor V (Leiden) mutation from genomic DNA using a homogeneous invader microtiter plate fluorescence resonance energy transfer (FRET) assay. J Mol Diagn. 2000;2(2):97-104. [pmid: 11272895].
45 Nauck M, Marz W, Wieland H. Evaluation of the Roche diagnostics LightCycler-Factor V Leiden Mutation Detection Kit and the LightCycler-Prothrombin Mutation Detection Kit. Clin Biochem. 2000;33(3):213-6. [pmid: 10913521].
46 Pecheniuk NM, Marsh NA, Walsh TP. Multiple analysis of three common genetic alterations associated with thrombophilia. Blood Coagul Fibrinolysis. 2000;11(2):183-9. [pmid: 10759012].
47 Benson JM, Ellingsen D, El-Jamil M, et al. Factor V Leiden and factor V R2 allele: high-throughput analysis and association with venous thromboembolism. Thromb Haemost. 2001;86(5):1188-92. [pmid: 11816705].
48 Parks SB, Popovich BW, Press RD. Real-time polymerase chain reaction with fluorescent hybridization probes for the detection of prevalent mutations causing common thrombophilic and iron overload phenotypes. Am J Clin Pathol. 2001;115(3):439-47. [pmid: 11242801].
49 Potter CG, Liu YT, Rees DC. Factor V Leiden mutation screened by PCR and detected with lanthanide-labeled probes. Genet Test. 2001;5(4):291-7. [pmid: 11960573].
50 Hung K, Sun X, Ding H, Kalafatis M, Simioni P, Guo B. A matrix-assisted laser desorption/ionization time-of-flight based method for screening the 1691G --> A mutation in the factor V gene. Blood Coagul Fibrinolysis. 2002;13(2):117-22. [pmid: 11914653].
51 Angeline T, Bentley HA, Hawk AB, et al. Prevalence of the Factor V G1691A and the Factor II/prothrombin G20210A gene polymorphisms among Tamilians. Exp Mol Pathol. 2005;79(1):9-13. [pmid: 15896772].
52 Meyer M, Kutscher G, Vogel G. The prothrombin nt20210 A allele as a risk factor for venous thromboembolism: detection of heterozygous and homozygous carriers by alternative methods. Thromb Res. 2000;97(5):359-63. [pmid: 10709912].
53 Gellings A, Holzem G, Wielckens K, Klingler KR. Prothrombin mutation: Employing the electrochemiluminescence technology of the elecsys(registered trademark) system for the detection of the point mutation at position 20210 in the 3′ untranslated region of the prothrombin gene. LaboratoriumsMedizin. 2001;25(1–2):26-30.
54 Gilchrist A, Solomon N, Erickson D, et al. Automated detection of the G20210A prothrombin mutation using the LCx microparticle enzyme immunoassay. Clin Chim Acta. 2001;314(1–2):249-54. [pmid: 11718704].
55 Humeny A, Bonk T, Berkholz A, Wildt L, Becker CM. Genotyping of thrombotic risk factors by MALDI-TOF mass spectrometry. Clin Biochem. 2001;34(7):531-6. [pmid: 11738388].
56 Endler G, Kyrle PA, Eichinger S, Exner M, Mannhalter C. Multiplexed mutagenically separated PCR: simultaneous single-tube detection of the factor V R506Q (G1691A), the prothrombin G20210A, and the methylenetetrahydrofolate reductase A223V (C677T) variants. Clin Chem. 2001;47(2):333-5. [pmid: 11159784].
57 Koksal V, Baris I, Etlik O. Primer-engineered multiplex PCR-RFLP for detection of MTHFR C677T, prothrombin G20210A and factor V Leiden mutations. Exp Mol Pathol. 2007;83(1):1-3. [pmid: 17275807].
58 Kowalski A, Radu D, Gold B. Colorimetric microwell plate detection of the factor V Leiden mutation. Clin Chem. 2000;46(8 Pt 1):1195-8. [pmid: 10926905].
59 Rhodes RB, Lewis K, Shultz J, et al. Analysis of the factor V Leiden mutation using the READIT Assay. Mol Diagn. 2001;6(1):55-61. [pmid: 11257212].
60 Moser MJ, Marshall DJ, Grenier JK, et al. Exploiting the enzymatic recognition of an unnatural base pair to develop a universal genetic analysis system. Clin Chem. 2003;49(3):407-14. [pmid: 12600952].
61 Murphy K, Hafez M, Philips J, Yarnell K, Gutshall K, Berg K. Evaluation of temperature gradient capillary electrophoresis for detection of the Factor V Leiden mutation: coincident identification of a novel polymorphism in Factor V. Mol Diagn. 2003;7(1):35-40. [pmid: 14529318].
62 Louis M, Dekairelle AF, Gala JL. Rapid combined genotyping of factor V, prothrombin and methylenetetrahydrofolate reductase single nucleotide polymorphisms using minor groove binding DNA oligonucleotides (MGB probes) and real-time polymerase chain reaction. Clin Chem Lab Med. 2004;42(12):1364-9. [pmid: 15576297].
63 Hertzberg M, Neville S, Favaloro E, McDonald D. External quality assurance of DNA testing for thrombophilia mutations. Am J Clin Pathol. 2005;123(2):189-93. [pmid: 15842041].
64 DelRio-LaFreniere SA, McGlennen RC. Simultaneous allele-specific amplification: a strategy using modified primer-template mismatches for SNP detection--application to prothrombin 20210A (factor II) and factor V Leiden (1691A) gene mutations. Mol Diagn. 2001;6(3):201-9. [pmid: 11571714].
65 Ozkan D, Erdem A, Kara P, et al. Allele-specific genotype detection of factor V Leiden mutation from polymerase chain reaction amplicons based on label-free electrochemical genosensor. Anal Chem. 2002;74(23):5931-6. [pmid: 12498186].
66 Lopez M, Giraldo P, Alvarez P, et al. Multiplex assay for genetic testing of thrombophilia: a method for routine clinical care. J Clin Lab Anal. 2007;21(6):349-55. [pmid: 18022930].
67 Patnaik M, Dlott JS, Fontaine RN, et al. Detection of genomic polymorphisms associated with venous thrombosis using the invader biplex assay. J Mol Diagn. 2004;6(2):137-44. [pmid: 15096570].
68 Schroell-Metzger B, Dicato M, Bosseler M, Berchem G. Comparison of standard PCR and the LightCycler technique to determine the thrombophilic mutations: an efficiency and cost study. Clin Chem Lab Med. 2003;41(4):482-5. [pmid: 12747590].
69 Mammo L, Sheereen A, Saour T, Saour J. Comparative study between the Light Cycler and the PCR-restriction fragment length polymorphism in detecting factor V Leiden and factor II 20210G>A mutations. Clin Biochem. 2006;39(7):767-9. [pmid: 16563366].
70 Cooper PC, Cooper SM, Smith JM, Kitchen S, Makris M. Evaluation of the Roche LightCycler: a simple and rapid method for direct detection of factor V Leiden and prothrombin G20210A genotypes from blood samples without the need for DNA extraction. Blood Coagul Fibrinolysis. 2003;14(5):499-503. [pmid: 12851538].
71 Behrens M, Lange R. A highly reproducible and economically competitive SNP analysis of several well characterized human mutations. Clin Lab. 2004;50(5–6):305-16. [pmid: 15209439].
72 Ozsoz M, Erdem A, Kerman K, et al. Electrochemical genosensor based on colloidal gold nanoparticles for the detection of Factor V Leiden mutation using disposable pencil graphite electrodes. Anal Chem. 2003;75(9):2181-7. [pmid: 12720360].
73 Huang TJ, Liu M, Knight LD, Grody WW, Miller JF, Ho CM. An electrochemical detection scheme for identification of single nucleotide polymorphisms using hairpin-forming probes. Nucleic Acids Res. 2002;30(12):e55. [pmid: 12060693].
74 Simundic AM, Topic E, Stefanovic M. Detection of factor V Leiden by PCR-SSCP using GMA precast Elchrom scientific gels. Clin Appl Thromb Hemost. 2003;9(3):227-31. [pmid: 14507111].
75 Sanders Sevall J. Factor V Leiden genotyping using real-time fluorescent polymerase chain reaction. Mol Cell Probes. 2000;14(4):249-53. [pmid: 10970729].
76 Liew M, Pryor R, Palais R, et al. Genotyping of single-nucleotide polymorphisms by high-resolution melting of small amplicons. Clin Chem. 2004;50(7):1156-64. [pmid: 15229148].
77 Verri A, Focher F, Tettamanti G, Grazioli V. Two-step genetic screening of thrombophilia by pyrosequencing. Clin Chem. 2005;51(7):1282-4. [pmid: 15976114].
78 Reyes AA, Ugozzoli LA, Lowery JD, et al. Linked linear amplification: a new method for the amplification of DNA. Clin Chem. 2001;47(1):31-40. [pmid: 11148174].
79 Castley A, Higgins M, Ivey J, Mamotte C, Sayer DC, Christiansen FT. Clinical applications of whole-blood PCR with real-time instrumentation. Clin Chem. 2005;51(11):2025-30. [pmid: 16166168].
80 El Housni H, Heimann P, Parma J, Vassart G. Single-nucleotide polymorphism genotyping by melting analysis of dual-labeled probes: examples using factor V Leiden and prothrombin 20210A mutations. Clin Chem. 2003;49(10):1669-72. [pmid: 14500596].
81 Vaughn CP, Elenitoba-Johnson KS. Hybridization-induced dequenching of fluorescein-labeled oligonucleotides: a novel strategy for PCR detection and genotyping. Am J Pathol. 2003;163(1):29-35. [pmid: 12819008].
82 Crockett AO, Wittwer CT. Fluorescein-labeled oligonucleotides for real-time pcr: using the inherent quenching of deoxyguanosine nucleotides. Anal Biochem. 2001;290(1):89-97. [pmid: 11180941].
83 Alsmadi OA, Bornarth CJ, Song W, et al. High accuracy genotyping directly from genomic DNA using a rolling circle amplification based assay. BMC Genomics. 2003;4(1):21. [pmid: 12777185].
84 Tsongalis GJ, Rainey BJ, Hodges KA. READIT: a novel technology used in the interrogation of nucleic acid sequences for single-nucleotide polymorphisms. Exp Mol Pathol. 2001;71(3):222-5. [pmid: 11733947].
85 Carmi N, Cohen D, Zvang E, Naparstek E, Deutsch V. Pronto ThromboRisk--a novel primer-extension ELISA based assay for the detection of mutations associated with increased risk for thrombophilia. J Clin Lab Anal. 2004;18(5):259-64. [pmid: 15356875].
86 Leyte A, Smits PH, van Straalen JP, van Doorn LJ, Quint WG. Automated, simultaneous detection of the factor V Leiden and prothrombin (G20210A) variants using multiplex PCR and a line probe assay. Thromb Haemost. 2000;83(2):354-5. [pmid: 10739403].
87 Schrijver I, Lay MJ, Zehnder JL. Diagnostic single nucleotide polymorphism analysis of factor V Leiden and prothrombin 20210G > A. A comparison of the Nanogen Eelectronic Microarray with restriction enzyme digestion and the Roche LightCycler. Am J Clin Pathol. 2003;119(4):490-6. [pmid: 12710121].
88 Erali M, Schmidt B, Lyon E, Wittwer C. Evaluation of electronic microarrays for genotyping factor V, factor II, and MTHFR. Clin Chem. 2003;49(5):732-9. [pmid: 12709363].
89 Evans JG, Lee-Tataseo C. Determination of the factor V Leiden single-nucleotide polymorphism in a commercial clinical laboratory by use of NanoChip microelectronic array technology. Clin Chem. 2002;48(9):1406-11. [pmid: 12194915].
90 French C, Li C, Strom C, et al. Detection of the factor V Leiden mutation by a modified photo-cross-linking oligonucleotide hybridization assay. Clin Chem. 2004;50(2):296-305. [pmid: 14656900].
91 French DJ, McDowell DG, Debenham P, Gale N, Brown T. HyBeacon probes for rapid DNA sequence detection and allele discrimination. Methods Mol Biol. 2008;429(-):171-85. [pmid: 18695966].
92 van den Bergh FA, van Oeveren-Dybicz AM, Bon MA. Rapid single-tube genotyping of the factor V Leiden and prothrombin mutations by real-time PCR using dual-color detection. Clin Chem. 2000;46(8 Pt 1):1191-5. [pmid: 10926904].
93 Hobson-Peters J, Toye P. A whole-blood homogeneous assay for the multiplex detection of the factor V G1691A and the prothrombin G20210A mutations. Mol Cell Probes. 2005;19(4):290-7. [pmid: 16006096].
94 Ameziane N, Lamotte M, Lamoril J, et al. Combined factor V leiden (G1691A) and prothrombin (G20210A) genotyping by multiplex real-time polymerase chain reaction using fluorescent resonance energy transfer hybridization probes on the Rotor-Gene 2000. Blood Coagul Fibrinolysis. 2003;14(4):421-4. [pmid: 12945887].
95 Baris I, Koksal V, Etlik O. Multiplex PCR-RFLP assay for detection of factor V Leiden and prothrombin G20210A. Genet Test. 2004;8(4):381-3. [pmid: 15684866].
96 Huber S, McMaster KJ, Voelkerding KV. Analytical evaluation of primer engineered multiplex polymerase chain reaction-restriction fragment length polymorphism for detection of factor V Leiden and prothrombin G20210A. J Mol Diagn. 2000;2(3):153-7. [pmid: 11229520].
97 Lucotte G, Champenois T. Duplex PCR-RFLP for simultaneous detection of factor V Leiden and prothrombin G20210A. Mol Cell Probes. 2003;17(5):267-9. [pmid: 14580402].
98 Corral J, Hernandez-Espinosa D, Soria JM, et al. Antithrombin Cambridge II (A384S): an underestimated genetic risk factor for venous thrombosis. Blood. 2007;109(10):4258-63. [pmid: 17244682].
99 Neitzel B, Matern C, Holinski-Feder E. Easy, accurate and reliable screening for SNPs by ion pair/reverse phase HPLC: simultaneous detection of factor V G1691A, prothrombin G20210A and methylenetetrahydrofolate reductase C677T variants. Clin Lab. 2003;49(7–8):313-8.
100 Ugozzoli LA, Hamby K. Four-color multiplex 5′ nuclease assay for the simultaneous detection of the factor V Leiden and the prothrombin G20210A mutations. Mol Cell Probes. 2004;18(3):161-6. [pmid: 15135449].
101 Jennings I, Kitchen S, Woods TA, Preston FE. Multilaboratory testing in thrombophilia through the United Kingdom National External Quality Assessment Scheme (Blood Coagulation) Quality Assurance Program. Semin Thromb Hemost. 2005;31(1):66-72. [pmid: 15706477].
102 Tripodi A, Chantarangkul V, Menegatti M, Tagliabue L, Peyvandi F. Performance of clinical laboratories for DNA analyses to detect thrombophilia mutations. Clin Chem. 2005;51(7):1310-1. [pmid: 15976128].
103 Lutz CT, Foster PA, Noll WW, et al. Multicenter evaluation of PCR methods for the detection of factor V Leiden (R506Q) genotypes. Clin Chem. 1998;44(6 Pt 1):1356-8. [pmid: 9625070].
104 Bravo-Osorio M, Bydlowski SP. Detection of methylenetetrahydrofolate reductase (MTHFR) C677T and prothrombin G20210A mutations: second restriction site for digestion control of PCR products. Clin Chim Acta. 2000;301(1–2):219-23. [pmid: 11020476].
105 Hessner MJ, Friedman KD, Voelkerding KV, et al. Multisite study for genotyping of the factor II (prothrombin) G20210A mutation by the invader assay. Clin Chem. 2001;47(11):2048-50. [pmid: 11673380].
106 Happich D, Madlener K, Schwaab R, Hanfland P, Potzsch B. Application of the TaqMan-PCR for genotyping of the prothrombin G20210A mutation and of the thermolabile methylenetetrahydrofolate reductase mutation. Thromb Haemost. 2000;84(1):144-5. [pmid: 10928490].
107 Preston FE, Kitchen S, Jennings I, Woods TA. A UK National External Quality Assessment scheme (UK Neqas) for molecular genetic testing for the diagnosis of familial thrombophilia. Thromb Haemost. 1999;82(5):1556-7. [pmid: 10595656].
108 Is recurrent venous thromboembolism more frequent in homozygous patients for the factor V Leiden mutation than in heterozygous patients?. Blood Coagul Fibrinolysis. 2003;14(6):523-9. [pmid: 12960604].
109 Baarslag HJ, Koopman MM, Hutten BA, et al. Long-term follow-up of patients with suspected deep vein thrombosis of the upper extremity: survival, risk factors and post-thrombotic syndrome. Eur J Intern Med. 2004;15(8):503-7. [pmid: 15668085].
110 Baglin T, Luddington R, Brown K, Baglin C. Incidence of recurrent venous thromboembolism in relation to clinical and thrombophilic risk factors: prospective cohort study. Lancet. 2003;362(9383):523-6. [pmid: 12932383].
111 Christiansen SC, Cannegieter SC, Koster T, Vandenbroucke JP, Rosendaal FR. Thrombophilia, clinical factors, and recurrent venous thrombotic events. JAMA. 2005;293(19):2352-61. [pmid: 15900005].
112 Eichinger S, Weltermann A, Mannhalter C, et al. The risk of recurrent venous thromboembolism in heterozygous carriers of factor V Leiden and a first spontaneous venous thromboembolism. Arch Intern Med. 2002;162(20):2357-60. [pmid: 12418950].
113 Gonzalez-Porras JR, Garcia-Sanz R, Alberca I, et al. Risk of recurrent venous thrombosis in patients with G20210A mutation in the prothrombin gene or factor V Leiden mutation. Blood Coagul Fibrinolysis. 2006;17(1):23-8. [pmid: 16607075].
114 Hoibraaten E, Mowinckel MC, de Ronde H, Bertina RM, Sandset PM. Hormone replacement therapy and acquired resistance to activated protein C: results of a randomized, double-blind, placebo-controlled trial. Br J Haematol. 2001;115(2):415-20. [pmid: 11703344].
115 Hron G, Eichinger S, Weltermann A, et al. Family history for venous thromboembolism and the risk for recurrence. Am J Med. 2006;119(1):50-3. [pmid: 16431184].
116 Lindmarker P, Schulman S, Sten-Linder M, Wiman B, Egberg N, Johnsson H. The risk of recurrent venous thromboembolism in carriers and non-carriers of the G1691A allele in the coagulation factor V gene and the G20210A allele in the prothrombin gene. DURAC Trial Study Group. Duration of Anticoagulation. Thromb Haemost. 1999;81(5):684-9. [pmid: 10365737].
117 Mansilha A, Araujo F, Severo M, Sampaio SM, Toledo T, Albuquerque R. Genetic polymorphisms and risk of recurrent deep venous thrombosis in young people: prospective cohort study. Eur J Vasc Endovasc Surg. 2005;30(5):545-9. [pmid: 16061406].
118 Prandoni P, Noventa F, Ghirarduzzi A, et al. The risk of recurrent venous thromboembolism after discontinuing anticoagulation in patients with acute proximal deep vein thrombosis or pulmonary embolism. A prospective cohort study in 1,626 patients. Haematologica. 2007;92(2):199-205. [pmid: 17296569].
119 Santamaria MG, Agnelli G, Taliani MR, et al. Thrombophilic abnormalities and recurrence of venous thromboembolism in patients treated with standardized anticoagulant treatment. Thromb Res. 2005;116(4):301-6. [pmid: 16038714].
120 Simioni P, Prandoni P, Lensing AW, et al. Risk for subsequent venous thromboembolic complications in carriers of the prothrombin or the factor V gene mutation with a first episode of deep-vein thrombosis. Blood. 2000;96(10):3329-33. [pmid: 11071624].
121 Strandberg K, Svensson PJ, Ohlin AK. Venous thromboembolism in carriers of the Factor V Leiden mutation and in patients without known thrombophilic risk factor; prediction of recurrence and APC-PCI complex concentration and/or soluble thrombomodulin antigen and activity. Thromb Res. 2007;121(2):145-51. [pmid: 17499343].
122 Vossen CY, Walker ID, Svensson P, et al. Recurrence rate after a first venous thrombosis in patients with familial thrombophilia. Arterioscler Thromb Vasc Biol. 2005;25(9):1992-7. [pmid: 15976329].
123 Wahlander K, Eriksson H, Lundstrom T, et al. Risk of recurrent venous thromboembolism or bleeding in relation to thrombophilic risk factors in patients receiving ximelagatran or placebo for long-term secondary prevention of venous thromboembolism. Br J Haematol. 2006;133(1):68-77. [pmid: 16512831].
124 Kearon C, Gent M, Hirsh J, et al. A comparison of three months of anticoagulation with extended anticoagulation for a first episode of idiopathic venous thromboembolism. N Engl J Med. 1999;340(12):901-7. [pmid: 10089183].
125 Kearon C, Julian JA, Kovacs MJ, et al. Influence of thrombophilia on risk of recurrent venous thromboembolism while on warfarin: Results from a randomized trial. Blood. 2008.
126 Miles JS, Miletich JP, Goldhaber SZ, Hennekens CH, Ridker PM. G20210A mutation in the prothrombin gene and the risk of recurrent venous thromboembolism. J Am Coll Cardiol. 2001;37(1):215-8. [pmid: 11153741].
127 Ridker PM, Miletich JP, Stampfer MJ, Goldhaber SZ, Lindpaintner K, Hennekens CH. Factor V Leiden and risks of recurrent idiopathic venous thromboembolism. Circulation. 1995;92(10):2800-2. [pmid: 7586244].
128 Eichinger S, Minar E, Hirschl M, et al. The risk of early recurrent venous thromboembolism after oral anticoagulant therapy in patients with the G20210A transition in the prothrombin gene. Thromb Haemost. 1999;81(1):14-7. [pmid: 10348706].
129 Middeldorp S, Meinardi JR, Koopman MM, et al. A prospective study of asymptomatic carriers of the factor V Leiden mutation to determine the incidence of venous thromboembolism. Ann Intern Med. 2001;135(5):322-7. [pmid: 11529695].
130 Simioni P, Tormene D, Prandoni P, et al. Incidence of venous thromboembolism in asymptomatic family members who are carriers of factor V Leiden: a prospective cohort study. Blood. 2002;99(6):1938-42. [pmid: 11877263].
131 Vossen CY, Conard J, Fontcuberta J, et al. Risk of a first venous thrombotic event in carriers of a familial thrombophilic defect. The European Prospective Cohort on Thrombophilia (EPCOT). J Thromb Haemost. 2005;3(3):459-64. [pmid: 15748234].
132 Couturaud F, Kearon C, Leroyer C, et al. Incidence of venous thromboembolism in first-degree relatives of patients with venous thromboembolism who have factor V Leiden. Thromb Haemost. 2006;96(6):744-9. [pmid: 17139368].
133 Simioni P, Prandoni P, Girolami A. Low rate of venous thromboembolism in asymptomatic relatives of probands with factor V Leiden mutation. Ann Intern Med. 1999;130(6):538. [pmid: 10075628].
134 Simioni P, Tormene D, Luni S, Caldato M, Girolami A. Clinical and laboratory expression of associated thrombophilic conditions (homozygous/heterozygous factor V Leiden mutation and heterozygous prothrombin variant 20210A) in an Italian family. Blood Coagul Fibrinolysis. 2000;11(4):379-84. [pmid: 10847426].
135 Samama MM, Simon D, Horellou MH, Trossaert M, Elalamy I, Conard J. Diagnosis and clinical characteristics of inherited activated protein C resistance. Haemostasis. 1996;26 Suppl 4:315-30. [pmid: 8979137].
136 Lensen R, Bertina RM, Vandenbroucke JP, Rosendaal FR. High factor VIII levels contribute to the thrombotic risk in families with factor V Leiden. Br J Haematol. 2001;114(2):380-6. [pmid: 11529860].
137 Rintelen C, Pabinger I, Bettelheim P, et al. Impact of the factor II: G20210A variant on the risk of venous thromboembolism in relatives from families with the factor V: R506Q mutation. Eur J Haematol. 2001;67(3):165-9. [pmid: 11737249].
138 Lensen R, Rosendaal F, Vandenbroucke J, Bertina R. Factor V Leiden: the venous thrombotic risk in thrombophilic families. Br J Haematol. 2000;110(4):939-45. [pmid: 11054086].
139 Le Cam-Duchez V, Gandrille S, Tregouet D, et al. Influence of three potential genetic risk factors for thrombosis in 43 families carrying the factor V Arg 506 to Gln mutation. Br J Haematol. 1999;106(4):889-97. [pmid: 10519989].
140 Middeldorp S, Henkens CM, Koopman MM, et al. The incidence of venous thromboembolism in family members of patients with factor V Leiden mutation and venous thrombosis. Ann Intern Med. 1998;128(1):15-20. [pmid: 9424976].
141 Meinardi JR, Middeldorp S, de Kam PJ, et al. The incidence of recurrent venous thromboembolism in carriers of factor V Leiden is related to concomitant thrombophilic disorders. Br J Haematol. 2002;116(3):625-31. [pmid: 11849222].
142 Vossen CY, Conard J, Fontcuberta J, et al. Familial thrombophilia and lifetime risk of venous thrombosis. J Thromb Haemost. 2004;2(9):1526-32. [pmid: 15333025].
143 Simioni P, Sanson BJ, Prandoni P, et al. Incidence of venous thromboembolism in families with inherited thrombophilia. Thromb Haemost. 1999;81(2):198-202. [pmid: 10063991].
144 Castaman G, Tosetto A, Cappellari A, Ruggeri M, Rodeghiero F. The A20210 allele in the prothrombin gene enhances the risk of venous thrombosis in carriers of inherited protein S deficiency. Blood Coagul Fibrinolysis. 2000;11(4):321-6. [pmid: 10847418].
145 Marik PE, Plante LA. Venous thromboembolic disease and pregnancy. N Engl J Med. 2008;359(19):2025-33. [pmid: 18987370].
146 Martinelli I, Legnani C, Bucciarelli P, Grandone E, De Stefano V, Mannucci PM. Risk of pregnancy-related venous thrombosis in carriers of severe inherited thrombophilia. Thromb Haemost. 2001;86(3):800-3. [pmid: 11583310].
147 Tormene D, Simioni P, Prandoni P, et al. Factor V Leiden mutation and the risk of venous thromboembolism in pregnant women. Haematologica. 2001;86(12):1305-9. [pmid: 11726323].
148 Tormene D, De Stefano V, Grandone E, et al. The G20210A prothrombin variant and the risk of venous thromboembolism or fetal loss in pregnant women: a family study. J Thromb Haemost. 2007;5(11):2193-6. [pmid: 17958738].
149 Martinelli I, Battaglioli T, De Stefano V, et al. The risk of first venous thromboembolism during pregnancy and puerperium in double heterozygotes for factor V Leiden and prothrombin G20210A. J Thromb Haemost. 2008;6(3):494-8. [pmid: 18182035].
150 Rodger MA, Carrier M, Keely E, et al. The management of thrombophilia during pregnancy: a Canadian survey. J Obstet Gynaecol Can. 2002;24(12):946-52. [pmid: 12464993].
151 Ridker PM, Goldhaber SZ, Danielson E, et al. Long-term, low-intensity warfarin therapy for the prevention of recurrent venous thromboembolism. N Engl J Med. 2003;348(15):1425-34. [pmid: 12601075].
152 Schulman S, Wahlander K, Lundstrom T, Clason SB, Eriksson H. Secondary prevention of venous thromboembolism with the oral direct thrombin inhibitor ximelagatran. N Engl J Med. 2003;349(18):1713-21. [pmid: 14585939].
153 Heshka J, Palleschi C, Wilson B, et al. Cognitive and Behavioural Effects of Genetic Testing for Thrombophilia. J Genet Couns. 2008.
154 Kaptein AA, van Korlaar IM, Cameron LD, Vossen CY, van der Meer FJ, Rosendaal FR. Using the common-sense model to predict risk perception and disease-related worry in individuals at increased risk for venous thrombosis. Health Psychol. 2007;26(6):807-12. [pmid: 18020855].
155 Saukko PM, Ellard S, Richards SH, Shepherd MH, Campbell JL. Patients' understanding of genetic susceptibility testing in mainstream medicine: qualitative study on thrombophilia. BMC Health Serv Res. 2007;7:82. [pmid: 17565670].
156 Saukko PM, Richards SH, Shepherd MH, Campbell JL. Are genetic tests exceptional? Lessons from a qualitative study on thrombophilia. Soc Sci Med. 2006;63(7):1947-59. [pmid: 16753245].
157 Bank I, Scavenius MP, Buller HR, Middeldorp S. Social aspects of genetic testing for factor V Leiden mutation in healthy individuals and their importance for daily practice. Thromb Res. 2004;113(1):7-12. [pmid: 15081560].
158 Wu O, Robertson L, Twaddle S, et al. Screening for thrombophilia in high-risk situations: systematic review and cost-effectiveness analysis. The Thrombosis: Risk and Economic Assessment of Thrombophilia Screening (TREATS) study. Health Technol Assess. 2006;10(11):1-110.
159 Auerbach AD, Sanders GD, Hambleton J. Cost-effectiveness of testing for hypercoagulability and effects on treatment strategies in patients with deep vein thrombosis. Am J Med. 2004;116(12):816-28. [pmid: 15178497].
160 Clark P, Twaddle S, Walker ID, Scott L, Greer IA. Cost-effectiveness of screening for the factor V Leiden mutation in pregnant women. Lancet. 2002;359(9321):1919-20. [pmid: 12057557].
161 Eckman MH, Singh SK, Erban JK, Kao G. Testing for factor V Leiden in patients with pulmonary or venous thromboembolism: a cost-effectiveness analysis. Med Decis Making. 2002;22(2):108-24. [pmid: 11958494].
162 Marchetti M, Quaglini S, Barosi G. Cost-effectiveness of screening and extended anticoagulation for carriers of both factor V Leiden and prothrombin G20210A. QJM. 2001;94(7):365-72. [pmid: 11435632].
163 Marchetti M, Pistorio A, Barosi G. Extended anticoagulation for prevention of recurrent venous thromboembolism in carriers of factor V Leiden--cost-effectiveness analysis. Thromb Haemost. 2000;84(5):752-7. [pmid: 11127850].
164 Sarasin FP, Bounameaux H. Decision analysis model of prolonged oral anticoagulant treatment in factor V Leiden carriers with first episode of deep vein thrombosis. BMJ. 1998;316(7125):95-9. [pmid: 9462312].
165 Coppens M, Reijnders JH, Middeldorp S, Doggen CJ, Rosendaal FR. Testing for inherited thrombophilia does not reduce the recurrence of venous thrombosis. J Thromb Haemost. 2008;6(9):1474-7. [pmid: 18540999].
166 Samama MM, Rached RA, Horellou MH, et al. Pregnancy-associated venous thromboembolism (VTE) in combined heterozygous factor V Leiden (FVL) and prothrombin (FII) 20210 A mutation and in heterozygous FII single gene mutation alone. Br J Haematol. 2003;123(2):327-34. [pmid: 14531916].
167 Hindorff LA, Burke W, Laberge AM, et al. Motivating factors for physician ordering of factor V Leiden genetic tests. Arch Intern Med. 2009;169(1):68-74. [pmid: 19139326].