# Results

## Results of the Search

The literature search process identified 13,711 citations that were potentially relevant to the Key Questions. An additional 165 articles were found by hand searching; thus, the total number of citations retrieved was 13,876 (see Figure 2). We excluded 6,099 duplicate citations. Most duplicates came from concurrently searching MEDLINE® and EMBASE®. The search strategy we used in EMBASE® was modeled on that which we used in MEDLINE®, with similar search terms. (see Appendix C). Also, the EMBASE® search engine allows the user to search the MEDLINE® database as well as EMBASE®. Using this strategy often leads to many duplicates between the two search sites. However, this Evidence-based Practice Center (EPC) employs this strategy in order to improve the sensitivity of the search.

Figure 2 Summary of literature search (number of articles)

* Total may exceed number in corresponding box, as articles could be excluded for more than one reason at this level.

**3 articles addressed both KQ3 and KQ4.

APC = activated protein C; CINAHL = Cumulative Index to Allied Health and Nursing Literature; DNA = deoxyribonucleic acid; FV Leiden = Factor V Leiden; KQ = Key Question; PT 20210A = prothrombin G20210A; VTE = venous thromboembolism

In the title review process, we excluded 5,553 citations that were ineligible for inclusion. In the abstract review process, we excluded 1,827 citations that did not meet one or more of the eligibility criteria (see the list in the Methods chapter, and Figure 2). At article review, we then excluded an additional 273 articles that did not meet one or more of the eligibility criteria. That left 124 articles eligible for inclusion in the review of one or more of the Key Questions.

### Description of Types of Studies Retrieved

No articles were identified that directly answered Key Question 1. One recent article nearly met our inclusion criteria and is described in Chapter 4.^42^ We identified 66 articles that were appropriate for Key Question 2. For Key Question 3, 23 articles were relevant to probands with the mutations, and 22 articles were relevant to family members with mutations. An additional 14 articles were identified relevant to Key Question 4, including 7 decision analyses.

## Key Question 1: Association of FVL testing, alone, or in combination with prothrombin G20210A testing, with improved clinical outcomes in adults with a personal history of VTE or in adult family members of mutation-positive individuals as a result of medical, personal, or public health decision making

We found no evidence that allowed us to directly answer this question.

## Key Question 2: Analytic validity of tests to identify FVL and prothrombin G20210A mutations

As described early in this report, we employed the same definition of analytic validity that is used in the Analytic Validity, Clinical Validity, Clinical Utility and Associated Ethical, Legal and Social Implications (ACCE) framework.29 Accordingly, our review of analytic validity assessed the analytic sensitivity (the analytic detection rate), analytic specificity, laboratory quality control, and assay robustness. Calculations of sensitivity and specificity, however, are most applicable to tests with dichotomous results. Given that there are two alleles, genetic test results have three outcomes: no mutations, a single mutation (heterozygous), or two mutations (homozygous). The studies we reviewed uniformly and appropriately described analytic validity as concordance or discordance between the experimental test and the reference standard, rather than sensitivity and specificity.

Study quality was generally high (see Appendix G, Evidence Table 1). In our quality assessment, we focused mainly on biases that could result from commercial conflicts of interest. The majority of these studies were published before journals began requiring disclosure of funding sources and potential conflicts of interest. More studies than not, however, did report on the source of funding; we considered these sources of funding to be unlikely to bias the results, since most of the reported funding was from governmental grant support.

Studies varied greatly in the extent to which they described the population from which the participants came; 17 studies adequately reported the setting or population from which the blood samples were obtained.43–46, 46–48, 48–57 Most described the experimental test adequately; approximately 60 to 70 percent of the studies gave a detailed description of their reference methods.

An important quality-related consideration was whether the study indicated whether the experimental test was conducted without knowledge of the reference standard results. In only a minority of the studies, the staff members were unaware of the reference standard results at the time they performed the experimental tests.46, 50, 52, 55, 58–64

The conventional “gold standard” method for Factor V Leiden (FVL) and prothrombin G20210A detection is the bidirectional sequencing of the specific genetic region of the gene of interest. The Food and Drug Administration (FDA) requires that manufacturers of new assays compare the assay to an established method and considers polymerase chain reaction and restriction fragment length polymorphism (PCR-RFLP) to be an acceptable reference standard. Indeed, many of the studies used PCR-RFLP or allele-specific polymerase chain reaction (AS-PCR) as their reference standards. In the absence of a substantial number of studies comparing the test under evaluation to the gold standard (bidirectional DNA sequencing), we included in our review studies that used traditionally accepted reference tests, typically PCR-RFLP or AS-PCR. We acknowledge that a “methods comparison” may be a lower level of evidence regarding analytic validity than a gold standard comparison would be.

All the studies included used blood as the source of DNA for analysis. In the table below, the studies are grouped according to the underlying chemical/biochemical experimental methods they employed (Tables 2-4; Appendix G, Evidence Tables 2-4). We observed a high level of concordance between the experimental methods and the reference standards, with many studies reporting 100 percent concordance (range of concordance, 98 to 100 percent).

Table 2 Analytic validity of testing for the FVL mutation

Experimental Test | Flap Endonuclease + FRET (Invader Assay) | FRET + Melting Curve Analysis (Light Cycler) | Taqman Real-Time PCR Assay | Electrochemical Genosensors | Temperature Gradient Capillary Electrophoresis | MALDI-TOF Mass Spectrometry | PCR-Single Strand Conformation Polymorphism | Simultaneous Allele-Specific Amplification Followed by RFLP | Fluorogenic Probe-Based Allelic Discrimination PCR Assay | Melting Analysis of Labeled Probes System | Lanthanide-Labeled Probe | Rolling Circle Amplification Assay Using Open Circle Probes Ligation | High-Resolution Melting Analysis of Small Amplicon | Pyro-sequencing | READIT SYSTEM (Pyrophosphorolysis) | ELISA | Reverse Allele-Specific Oligonucleotide (ASO) Hybridization Assay | First Nucleotide Change Technology | Linked Linear Amplification -ASO Capture | Nanochip Electronic Microarray | Photo-Cross-Linking Oligonucleotide Hybridization Assay | MGB-NFQ Probes (7700 SDS) | Single-and Dual-Labeled HyBeacon Probes
Reference Standard | AS-PCR or PCR-RFLP | PCR or PCR-RFLP | PCR-RFLP | PCR-RFLP | PCR-RFLP | PCR-RFLP | PCR-RFLP | PCR-RFLP | PCR-RFLP | PCR-RFLP or Conventional Dual-Hybridization Probe Genotyping | PCR-RFLP | PCR-RFLP | Light Cycler | LightCycler or Direct Sequencing | PCR-RFLP or Not Specified | Direct Sequencing or PCR-RFLP | PCR-RFLP | PCR-RFLP | PCR-RFLP & PCR-ASO | PCR-RFLP, Light Cycler, Invader Monoplex Assay | PCR-Based Assay | FRET + Melting Curve Analysis (LightCycler) | RFLP or the Roche FVL Hybridization Probe Kit
Studies | Hessner, 2000^43^ Ledford, 2000^44^ Patnaik, 2004^67^ | Schroell-Metzger, 2003^68^ Mammo, 2006^69^ Cooper, 2003^70^ Nauck, 2000^45^ Parks, 2001^48^ | Louis, 2004^62^ Benson, 2001^47^ Behrens, 2004^71^ | Ozkan, 2002^65^ Ozsoz, 2003^72^ Huang, 2002^73^ | Murphy, 2003^61^ | Hung, 2002^50^ Humeny, 2001^55^ | Simundic, 2003^74^ | DelRio-LaFreniere, 2001^64^ | Sanders, 2000^75^ | El Housni, 2003^80^ (dual-labeled probes); Vaughn, 2004^81^ Crockett, 2001^82^ (single-labeled fluorophore-based systems) | Potter, 2001^49^ | Alsmadi, 2003^83^ | Liew, 2004^76^ | Verri, 2005^77^ | Tsongalis, 2001^84^ Rhodes, 2001^59^ | Lopez, 2007^66^ Carmi, 2004^85^ | Kowalski, 2000^58^ Leyte, 2000^86^ | Pecheniuk, 2000^46^ | Reyes, 2001^78^ | Schrijver, 2003^87^ Erali, 2003^88^ Evans, 2002^89^ | French, 2004^90^ | Castley, 2005^79^ | French, 2008^91^
Total Population * | 1369 + 371 + 368 | 132 + 2131 + 200 + 110 + 155 | 115 + 100 + 100 | 90 + 90 + NR | 304 | 27 + 70 | 150 | 49 | 120 | 100 + 100 + 100 | 379 | 216 | 104 | 100 | 280 + 510 | 264 + 284 | 256 + 99 | 500 | 111 | 197 for the comparison to RFLP and 195 + 224 + 758 for the comparison to LightCycler | 1054 | 151 | > 500
Concordance | 99.5% – 100% | 100% | 100% | 93% – 100% | 99.3% | 100% | 100% | 100% | 100% | 100% | 99–100% | 99.4% | 100% | 100% | 99–100% | 95–100% | 100% | 100% | 100% | 98–100% | 98.6% | 100% | 100%
Source of Zygosity Discordance ** | 5 samples were typed WT by reference standard but heterozygous by Invader assay. With retyping, there was concordance, with all genotypes unequivocally WT. In Ledford, 2 samples were discordant. Retesting yielded results concordant with the original PCR-RFLP results. In one case, a heterozygous sample was called homozygous by the Invader assay; the discrepancy was due to a failure to add genomic DNA to the well. In the second case, a heterozygous sample was called WT. | NA | NA | In Ozkan et al., the source and nature of the 7% discordance were not explained. Ozsoz et al. reported neither reference standard nor quantitative results. Rather, it stated that there was "good agreement" and ongoing work to achieve 100% accuracy. Huang et al. did not report sample size or reference standard. | One heterozygous sample falsely identified as homozygous mutant by TGCE. One WT/WT falsely reported as WT/Leiden by TGCE. | NA | NA | NA | NA | NA | Not reported, but at least 4 samples (1%) were discordant on the first test, and 1 (0.26%) remained discordant on repeat testing. | Not reported | NA | NA | Unclear (in Tsongalis et al., one discordant result was due to an equivocal relative light unit, while the other was indeterminate); NA59 | No explanation was given as to the source of the discrepancies in Lopez et al.; NA85 | NA | NA | NA | NA87, 88; In Evans et al., the reference test did not correctly identify 17 samples (details as in footnote). | [underlined: 2 false-negatives]: For one, the reference indicated homozygous, but the experimental reported heterozygous. For the other, the reference indicated heterozygous, but the experimental test indicated WT. Repeat testing confirmed the results of the reference standard for both. [underlined: False-positives]: Reference indicatedWT, but the experimental test reported heterozygous initially. Repeat testing confirmed WT. | NA
Did Repeating Resolve the Discordance * ? | Yes (technical/operator error) | NA | NA | Not reported | Yes for the heterozygous; did not resolve for the WT/WT (see footnote) | NA | NA | NA | NA | NA | Yes, but not all | Yes (if tests were performed in triplicate). | NA | NA | Yes84; NA59 | Yes | NA | NA | NA | NA87, 88; No89 | Yes; 15 samples were discordant. All 15 samples were genotyped correctly (i.e., 100% concordance) upon retesting (reextraction of genomic DNA; resolution of the indeterminate, invalid, and discordant samples). | NA | n/a

* the order of the counts corresponds to the order of the studies in the row above;

** if <100% concordance ASO = allele-specific oligonucleotide; AS-PCR = allele-specific PCR; DNA = deoxyribonucleic acid; ELISA = enzyme-linked immunosorbent assay; FRET = fluorescence resonance energy transfer; FVL = Factor V Leiden; MALDI-TOF = matrix-assisted laser desorption/ionization – time of flight; MGB-NFQ = minor groove–binding non-fluorescent quencher; NA = not applicable; NR = not reported; PCR = polymerase chain reaction; READIT = reversed enzyme activity DNA interrogation test; RFLP = restriction fragment length polymorphism; SDS = sequence detection system; TGCE = temperature gradient capillary electrophoresis; WT = wild-type

Table 3 Details of studies on the analytic validity of testing for the FVL mutation

Study(s), Year(s) | Description
Hessner, 2000^43^ | Seven samples (0.5%) were classified as equivocal; upon retesting, they were correctly typed as WT/WT (1691GG). Also, 16 samples (1.2%) generated invalid results because of unacceptable signal strength. These 16 samples were repeated from the same DNA preparations, and all were successfully typed as WT/WT.
Louis, 2004^62^ | The aim of the study was to assess the cost-effectiveness and specificity of a high-throughput real-time PCR assay based on allele-specific fluorescent oligonucleotides that contain a 3′ minor groove binding (MGB) probe.
Benson, 2001^47^ | 6295 adult subjects from a large managed-care population in Southern California were analyzed for FVL and the R2 allele; a discrepancy rate of 0% was found on duplicate testing for all results different from WT among the first 1000 samples; the first 100 heterozygous/homozygous samples were also analyzed by the traditional method involving restriction digestion followed by GeneScan analysis, with complete agreement between both analyses.
Murphy, 2003^61^ | A low PCR product peak height on initial TGCE analysis was the source of the false homozygous result noted above. The heterozygosity was confirmed by repeat testing using both methodologies. The false WT/Leiden involved a G->A mutation 95 bases downstream of the Leiden site. Thus, this sample was WT/WT for Leiden allele but contained a new polymorphism in close proximity to Leiden position that caused the sample to be reported as heterozygous by TGCE.
Huang, 2002^73^ | A method to identify SNP alterations by combining hairpin-forming DNA probes and electrochemical detection of sandwich DNA hybridization was reported. The results obtained using electrochemical detection of mismatches in nucleic acids (EDEMNA) agreed completely with the results determined independently at the UCLA Diagnostic Molecular Pathology Laboratory.
Hung, 2002^50^ | A matrix-assisted laser desorption/ionization time-of-flight (MALDI/TOF) method was used. Blood samples were collected from 11 healthy controls and 16 patients with activated protein C resistance. The genotype of all 12 heterozygous and 4 homozygous FVL individuals was not known to the MALDI-TOF group before genotyping of all samples was completed.
Humeny, 2001^55^ | Samples: Women from the Obstetrics and Gynecology outpatient clinic who presented with various endocrine problems.
Potter, 2001^49^ | Detection of FVL w/lanthanide-labeled probe: an assay using oligonucleotide probes for normal and mutant sequences, labeled with europium and samarium, respectively, and measured by time-resolved fluorescence.
Verri, 2005^77^ | Failure to make a genotype call at the first attempt was infrequent (about 5%) and was mostly attributable to insufficient signal-to-noise ratios caused by poor PCR amplification.
Tsongalis, 2001^84^ | The Reversed Enzyme Activity DNA Interrogation Test (READIT) System was claimed to offer the following advantages: (1) rapid SNP analysis, (2) accuracy and precision, (3) cost effectiveness, (4) decreased turn-around times, (5) high throughput, and (6) excellent analysis software.
Rhodes, 2001^59^ | Residual coded samples (n=510) from three independent laboratories were analyzed in a blinded format for mutations in the Factor V gene using the READIT Assay. A blinded retrospective analysis of the FVL mutation generated by independent laboratories was used to determine the concordance.
Reyes, 2001^78^ | A simple LLA model might not hold true for all situations (e.g., degradation of downstream primer extension products might not be complete at each cycle because of premature termination of primer extension or <100% efficiency of the polymerase 5′-3′ exonuclease activity. Results of a simulated amplicon contamination experiment showed that LLA carryover amplification efficiency was substantially lower than that seen in PCR. In practical terms, this suggests that LLA is less susceptible than PCR to false-positive results that are attributable to amplicon contamination.
Schrijver, 2003^87^ | Some of the samples failed to amplify with the NanoChip system. In some of these cases, the authors were unable to re-run the analysis because there was no sample remaining. The others failed re-amplification on the NanoChip System.
Evans, 2002^89^ | Of the 635 samples classified by the Third Wave Assay (Invader Monoplex Assay) as FV WT, 10 were identified as heterozygous FVL by the NanoChip technique. Similarly, of the 114 putative heterozygous samples, 4 were identified as WT by the NanoChip technique. Of the 9 reported homozygous samples, 6 were homozygous, 2 were heterozygous, and 1 was FV WT by the NanoChip assay. All 17 results that were discordant with the Third Wave analysis were confirmed by DNA sequencing to be correctly classified by the NanoChip technology. The Nanochip system was 100% accurate in characterizing WT/WT, heterozygous, and homozygous samples, as compared to accuracies of 99.2%, 90.2%, and 100% for the comparable Third Wave analyses.
Castley, 2005^79^ | MGB-NFQ: minor groove–binding nonfluorescent quencher; 7700 SDS: ABI PrismTM 7700 sequence detection system.
Mammo, 2006^69^ El Housni, 2003^80^ Verri, 2005^77^ Pecheniuk, 2000^46^ | Samples reported were FVL and prothrombin G20210A combined.

DNA = deoxyribonucleic acid; EDEMNA = electrochemical detection of mismatches in nucleic acids; FVL = Factor V Leiden; LLA = linked linear amplification; MALDI-TOF = matrix-assisted laser desorption/ionization – time of flight; MGB-NFQ = minor groove–binding non-fluorescent quencher; PCR = polymerase chain reaction; READIT = Reversed Enzyme Activity DNA Interrogation Test; SDS = sequence detection system; SNP = single nucleotide polymorphism; SSCP = single strand conformation polymorphism; TGCE = temperature gradient capillary electrophoresis; UCLA = University of California at Los Angeles; WT = wild-type.

Table 4 Analytic validity of testing for prothrombin G20210A

Experimental Test | PCR-RFLP | Flap Endonuclease + FRET (Invader Assay) | FRET + Melting Curve Analysis (Light Cycler) | Taqman Real-Time PCR Assay | Electro-chemical Detection | Single Strand Conformation Polymorphism (SSCP) and Denaturing Gradient Gel Electrophoresis (DGGE) | MALDI-TOF Mass Spectrometry | SASA-PCR Followed by RFLP | ELISA | Rolling Circle Amplification Assay Using Open Circle Probes Ligation | First Nucleotide Change Technology | Nanochip Electronic Microarray | High-Resolution Melting Analysis of Small Amplicon | MGB-NFQ Probes (7700 SDS)
Reference Standard | PCR-RFLP | PCR-RFLP or AS-PCR | PCR or PCR-RFLP | PCR-RFLP | PCR-RFLP | Direct DNA Sequencing | Sequencing | PCR-RFLP | Direct Sequencing or PCR-RFLP | PCR-RFLP | PCR-RFLP | PCR-RFLP & Light Cycler | Light Cycler | FRET + Melting Curve Analysis (LightCycler)
Studies (ref. no.) | Bravo-Osorio, 2000^104^ | Hessner, 2004^105^ Patnaik, 2004^67^ | Schroell-Metzger, 2003^68^ Cooper, 2003^70^ Nauck, 2000^45^ Parks, 2001^48^ | Louis, 2004^62^ Happich, 2000^106^ Behrens, 2004^71^ | Gellings, 2001^53^ | Meyer, 2000^52^ | Humeny, 2001^55^ | DelRio-LaFreniere, 2001^64^ | Lopez, 2007^66^ Gilchrist, 2001^54^ Carmi, 2004^85^ | Alsmadi, 2003^83^ | Pecheniuk, 2000^46^ | Schrijver, 2003^87^ Erali, 2003^88^ | Liew, 2004^76^ | Castley, 2005^79^
Total Population * | 98 | 522 + 377 | 132 + 200 + 110 + 157 | 122 + 233 + 100 | 12 | 527 | 11 | 50 | 122 + 459 + 283 | 298 | 500 | 199 for the comparison to RFLP and 198 + 224 for the comparison to LightCycler | 22 | 310
Concordance | 100% | 100% | 100% | 100% | 100% | 100% (based on 8 samples) | 100% | 100% | 98–100% | 99.5% | 99% | 100% | 100% | 100%
Source of Zygosity Discordance ** | NA | NA | NA | NA | NA | NA | NA | NA | No explanation of discrepancies in Lopez.54 Sensitivity was 100% with no false negatives, specificity was 99.2% with 2 false positives; 2 samples corrected on second attempt. | Not reported | No explanation was given on the source of discrepancies. | NA | | NA
Did Repeating Resolve the Discordance ** ? | NA | NA | NA | NA | NA | NA | NA | NA | Yes66, 85, NA54 | Yes (If tests were performed in triplicate). | Unclear: 1% misclassification was in accordance with 2.2% error noted when establishing the cut-off criteria. | NA | | NA

* the order of the counts corresponds to the order of studies in the row above;

** if <100% concordance

AS-PCR = allele-specific PCR; DGGE = denaturing gradient gel electrophoresis; DNA = deoxyribonucleic acid; ELISA = enzyme-linked immunosorbent assay; FRET = fluorescence resonance energy transfer; MALDI-TOF = matrix-assisted laser desorption/ionization – time of flight; MGB-NFQ = minor groove–binding non-fluorescent quencher; NA = not applicable; PCR = polymerase chain reaction; RFLP = restriction fragment length polymorphism; SASA-PCR = simultaneous allele-specific amplification PCR; SDS = sequence detection system; SSCP = single strand conformation polymorphism

Outliers were the results reported by Ozkan et al.65 and by Lopez et al.,66 which detected FVL using electrochemical and enzyme-linked immunosorbent assay (ELISA) methods, respectively. In many studies, the discordances resolved after the tests were repeated. We describe the studies in detail below.

### Detection of FVL

Forty-one studies compared at least two methods for FVL detection (Tables 2 and 3; Appendix G, Evidence Table 2). Three studies compared flap endonuclease combined with fluorescence resonance energy transfer (FRET/invader assay) to the reference standard.43, 44, 67 The concordance ranged from 99.5 percent to 100 percent. Five samples were typed as wild-type by the reference standard but were initially found to be heterozygous by the invader assay. Retyping of these samples by both methods was concordant, with all genotypes being unequivocally wild-type. In Ledford et al.,44 two samples were discordant with the PCR-RFLP method. Repeating both the invader and PCR-RFLP testing yielded results concordant with the original PCR-RFLP results. In one case, in which a heterozygous sample was called homozygous mutant by the invader assay, the discrepancy was due to a failure to add genomic DNA to the well. In the second case, a heterozygous sample was called wild-type, and there was no obvious cause for the discrepancy. The source of discordance was reported to be technical or operator errors.

Five studies compared FRET combined with melting curve analysis (Light Cycler Assay) to the reference standard.45, 48, 68–70 The concordance was 100 percent for all four studies.

Three studies compared Taqman real time polymerase chain reaction (PCR) to PCR-RFLP.47, 62, 71 The concordance was again 100 percent in all these studies.

In three studies, electrochemical genosensors were used to detect the FVL mutation in a research, rather than a clinical setting.65, 72, 73 The concordance ranged from 93 percent to 100 percent. In the study by Ozkan et al., the source and nature of the 7 percent discordance were not explained.65 The study by Ozsos et al. reported neither the reference standard nor quantitative results.72 Rather, the authors stated that there was "good agreement" between the experimental and reference methods and that efforts to achieve 100 percent accuracy were underway. Huang et al. did not report the sample size or specify the reference standard.73

Murphy et al., in a study with more than 300 samples, used temperature gradient capillary electrophoresis (TGCE) technology to detect FVL.61 One heterozygous sample was falsely identified as being homozygous by TGCE but was corrected in repeat testing. A low PCR product peak height on the initial capillary electrophoresis analysis was identified as the source of the false homozygous result. One wild-type sample was falsely reported as being heterozygous by TGCE. Repeating the tests did not resolve this inconsistency. Further investigation revealed that the false heterozygous mutation involved a G → A mutation 95 base pairs downstream of the Leiden site. Thus, this sample was really wild-type for the Leiden allele but contained a new polymorphism in close enough proximity to the Leiden position that TGCE detected it as a heterozygous mutant.

Two small studies used mass spectrometry to detect FVL and reported 100 percent concordance.50, 55 There are several single studies, each of which compared a research-based experimental method to the reference standard and reported a concordance of 100 percent.46, 64, 74–79 Three studies used a fluorophore probe to detect FVL,80–82 and all three reported 100 percent concordance. Potter et al. tested a lanthanide-labeled probe for FVL detection.49 There was a 1 percent discordance on the first test, and 0.26 percent remained discordant after repeating the test. Alsmadi et al. tested the rolling circle amplification assay using open circle probes ligation and reported a 99.4 percent concordance rate with PCR-RFLP.83

Taking advantage of pyrophosphorolysis chemistry, Tsongalis84 and Rhodes59 used the Reversed Enzyme Activity DNA Interrogation Test (READIT) System for FVL detection.59, 84 The concordance rate was greater than 99 percent when compared to the reference standard. Tsongalis et al. reported one discordant result that was due to an equivocal relative light unit and another that was indeterminate.84

Two studies used ELISA to detect FVL:66, 85 Carmi et al.85 reported 100 percent concordance with the reference method. The initial concordance in the other study was just 95 percent.66 No explanation was given regarding the source or nature of the discrepancies. Upon repeat testing, the discordance resolved.

Three studies compared nanochip electronic microarray technology to various reference standards for the detection of FVL.87–89 Two reported 100 percent concordance rates.87, 88 Interestingly, in the study by Evans et al., of the 635 samples classified by the Third Wave Assay (Invader Monoplex Assay) as wild-type, 10 were identified as heterozygous FVL by the NanoChip technique.89 Similarly, of the 114 putative heterozygous samples, 4 were identified as wild-type by the NanoChip technique. Of the 9 reported homozygous samples, 6 were read as homozygous, 2 as heterozygous, and 1 as wild-type by the NanoChip assay. All 17 results that were discordant were confirmed by DNA sequencing to have been correctly classified by the NanoChip technology. Compared to DNA sequencing, the NanoChip system was 100 percent accurate in characterizing wild-type, heterozygous, and homozygous samples, as compared to accuracies of 99.2, 90.2, and 100 percent for the comparable Third Wave analyses.

### Detection of Prothrombin G20210A

The concordance rates between the experimental methods and the reference standards for the detection of prothrombin G20210A were 100 percent in nearly all of the 23 studies (Tables 4 and 5, Appendix G, Evidence Table 3). Three studies had some initial discordance between ELISA and direct sequencing or PCR-RFLP (0 to 2 percent), which upon repetition completely resolved.54, 66, 85 Alsmadi et al. and Pecheniuk et al. reported concordance rates of 99.5 and 99 percent, respectively.46, 83

Table 5 Details of studies on analytic validity of testing for prothrombin G20210A

Study(s), Year(s) | Description
Bravo-Osorio, 2000^104^ | Since control of digestion is of importance to avoid false results in RFLP, this study described a method for detecting prothrombin G20210A and methylenetetrahydrofolate reductase (MTHFR) mutations, in which a second restriction site was introduced in order to control the enzyme digestion of the respective PCR products. There were 49 individuals with either a prothrombinG20210A or MTHFR mutation, and 49 individuals with neither mutation as negative controls. Those performing the tests were aware of the results.
Patnaik, 2004^67^ | AS-PCR reference standard mistyped 14 samples that the invader experimental assay typed correctly.
Louis, 2004^62^ | The aim of the study was to assess the cost-effectiveness and specificity of a high-throughput real-time PCR assay based on allele- specific fluorescent oligonucleotides that contain a 3′ minor groove binding (MGB) probe.
Happich, 2000^106^ | Samples of 233 individuals previously genotyped for PT-G20210A and MTHFR by restriction fragment analysis were re-analyzed by the 5′nuclease fluorescence assay (Taqman).
Gellings, 2001^53^ | Genotype was determined based on the electrochemiluminescence signal generated by the ruthenium complex from the 5′ primer.
Meyer, 2000^52^ | A series of 383 patients with thrombosis and 144 controls were tested with SSCP and DGGE. Eight of the normal samples, the heterozygous samples, and the homozygous samples were tested with direct DNA sequencing, and the results were confirmed. The prevalence of prothrombin mutation in thrombotic and healthy patients was reported.
Humeny, 2001^55^ | Sample: women from the Obstetrics and Gynecology outpatient clinic who presented with various endocrine problems.
Gilchrist, 2001^54^ | Only 100 patients were tested with RFLP, although 459 patients were tested with microparticle enzyme immunoassay (MEIA).
Pecheniuk, 2000^46^ | Samples reported FVL and prothrombin G20210A combined.
Erali, 2003^88^ | Two prothrombin samples were identified as containing mutations at sites other than position 20210. Both were WT at 20210, but one was heterozygous at A20218G and the other at C20209T. Both were correctly identified as WT G20210 in the NanoChip system, but the fluorescence signal for the WT probe was approximately one-half of the signal for the WT control sample. The most likely explanation for the lower signal is that the WT probe was binding only to the exact WT strand and did not bind to the strand with the A20218G mutation. The mutant probe did not bind to either strand.
Castley, 2005^79^ | The goal of the study was to show that whole-blood PCR after formamide addition is as good as DNA-extracted PCR (DNA EXTRACTION). There were two comparisons: (1) whole blood vs. DNA-extracted real-time detection (RTD) PCR comparison (concordance results in Tables 2 and 3 of online Data Supplement [not available in this program]). (2) Whole-blood comparison between RTD-PCR and SDS. MGB-NFQ: minor groove–binding nonfluorescent quencher, 7700 SDS: ABI PrismTM 7700 sequence detection system.

AS-PCR = allele-specific PCR; DGGE = denaturing gradient gel electrophoresis; DNA = deoxyribonucleic acid; FVL = Factor V Leiden; MEIA = microparticle enzyme immunoassay; MGB-NFQ = minor groove–binding non-fluorescent quencher; MTHFR = methylenetetrahydrofolate reductase; PCR = polymerase chain reaction; PT-G20210A = prothrombin G20210A mutation; RFLP = restriction fragment length polymorphism; RTD = real-time detection; ; SDS = sequence detection system; SSCP = single strand conformation polymorphism; WT = wild-type.

### Simultaneous Detection of FVL and Prothrombin G20210A Mutations

All 12 studies that employed multiplex technologies for the simultaneous detection of the two mutations reported 100 percent concordance between these technologies and the matched reference standard (Tables 6 and 7; Appendix G, Evidence Table 4).51, 56, 86, 92–100

Table 6 Analytic validity of simultaneous detection (multiplex) of FVL and prothrombin G20210A mutations

Experimental Test | FRET + melting Curve Analysis (Light Cycler) | Mutagenically Separated PCR Followed by Gel Electrophoresis | Multiplex PCR- RFLP | Multiplex PCR – Reverse Hybridization Line Probe Assay | Multiplex AS-PCR - Ion-Pair Reversed Phase HPLC | Multiplex PCR with ASO Hybridization Using the 5′ Nuclease Assay
Reference Standard | PCR-RFLP | PCR-RFLP | PCR-RFLP or Light Cycler | PCR-RFLP | PCR-RFLP | PCR-RFLP
Studies (ref. no.) | van den Bergh, 2000^92^ Hobson- Peters, 2005^93^ Ameziane, 2003^94^ | Endler, 2001^56^ | Baris, 2004^95^ Angeline, 2005^51^ Huber, 2000^96^ Lucotte, 2003^97^ Koksal, 2007^57^ | Leyte, 2000^86^ | Nietzel, 2003^99^ | Ugozzoli, 2004^100^
Total Population * | 47 + 43 + 200 | 153 | 408 + 72 + 205 + 175 + 104 | 99 | > 100 | 52
Concordance | 100% | 100% | 100% | 100% | 100% | 100%
Source of Zygosity Discordance ** | NA | NA | NA | NA | NA | NA
Did Repeating Resolve the Discordance ** ? | NA | NA | NA | NA | NA | NA

* The order of the counts corresponds to the order of studies in the row above;

** if <100% concordance

ASO = allele-specific oligonucleotide; AS-PCR = allele-specific PCR; FRET = fluorescence resonance energy transfer; HPLC = high performance (pressure) liquid chromatography; NA = not applicable; PCR = polymerase chain reaction; RFLP = restriction fragment length polymorphism

Table 7 Details of studies on the analytic validity of simultaneous detection (multiplex) of FVL and prothrombin G20210A mutations

Study(s), Year(s) | Description
Hobson-Peters, 2005^93^ | Used FRET with a dual-probe quenching system that is similar to the Light Cycler assay.
Endler, 2001^56^ | 70 known patients with recurrent venous thrombosis and 83 selected healthy controls from the Austrian Study of Recurrent VTE for whom previous determination of the genotypes for the FV:R506Q (G1691A), the FII:G20210A, and MTHFR:A223V (C677T) variants had been established by PCR followed by RFLP
Baris, 2004^95^ | No reference method was reported. For concordance, known patients with recurrent venous thrombosis with "previously determined" genotypes for FVL and prothrombin G20210A were used. FVL was amplified significantly less than prothrombinG20210A, with an initial primer concentration of 2:1. The effects of various factors, including magnesium cation concentration, primer concentration, and PCR cycling conditions, on PCR specificity and efficiency were determined and optimized in this study.
Huber, 2000^96^ | Concordance was only tested on FVL. For prothrombin, the multiplex PCR-RFLP identified 9 heterozygous and 196 wild-type samples. To independently verify prothrombin results, DNA sequencing confirmed 9 heterozygous mutant and 11 wild-type samples (10% of the sample). The study also genotyped 123 samples with multiplex PCR-RFLP and the invader assay for Factor II, with 100% concordance.
Lucotte, 2003^97^ | Duplex PCR-RFLP for simultaneous detection of FVL and prothrombin G20210A was used.
Koksal, 2007^57^ | Significantly less amplification was noted for FV relative to prothrombin; the FV primer was therefore 2x concentrated relative to prothrombin.

DNA = deoxyribonucleic acid; FII = Factor II; FV = Factor V; FRET = fluorescence resonance energy transfer; FVL = Factor V Leiden; MTHFR = methylenetetrahydrofolate reductase; PCR = polymerase chain reaction; RFLP = restriction fragment length polymorphism; VTE = venous thromboembolism

### External Quality Assurance

We identified three studies that addressed external quality assurance or laboratory performance relative to the gold standards.63, 101, 102 Studies assessing quality assurance that were published before the year 2000 were excluded by our search strategy, including that by Lutz et al.103

Jennings et al have described the results of the United Kingdom National External Quality Assessment Scheme (UK NEQAS) Thrombophilia Screening Program.101 Two hundred eighty centers participated in the thrombophilia screening exercises. This group reported the details of their first three evaluation exercises in an earlier publication by Preston et al.107 They described an important error rate in 6 years of UK NEQAS experience.107 Among centers performing genetic analysis for FVL and the prothrombin mutation, an error rate of 3 to 6 percent was identified, with both transcription and analytical errors being observed. For example, a staff member transcribing the wrong genotype in preparing a report of the results was considered a transcription error; misinterpretation of the results of the testing procedure was an analytic error.

Hertzberg et.al. have reported the results of The Royal College of Pathologists of Australasia’s external quality assurance program.63 This program sent 133 DNA samples with known mutations to laboratories in 10 separate surveys. For the 3,799 responses received, the overall successful identification rate was 98.63 percent; the poorest individual sample result was a 15 percent incorrect identification of a homozygous FVL sample. Success rates in identifying specific mutations were 98.13 percent for FVL and 98.84 percent for prothrombin G20210A. Of the 39 responding laboratories, 20 (51 percent) made at least one error. Importantly, 3 of the 39 laboratories were responsible for 46 percent of all errors.

Finally, Tripodi et al.102 confirmed the findings of Preston et al.107 described above. Their survey was organized by the Subcommittee on Hemostasis of the Italian Committee for Standardization of Laboratory Tests (CISMEL). They sent four samples with known genotypes to 52 participating laboratories and received 41 responses. One laboratory misidentified a heterozygous FVL as a wild-type specimen, one misidentified a homozygote as a heterozygote, and one misidentified a heterozygote as a homozygote. Eight samples were given no interpretation. Similarly, one wild-type prothrombin G21210A was called a heterozygote, four heterozygotes were misclassified, and one homozygote was called heterozygote, with 10 being uninterpreted. The authors concluded that regular quality control programs aimed at identifying causes of failure are warranted.

### Summary of the Evidence for Key Question 2

- There was high-grade evidence that tests for the detection of FVL have excellent analytic validity.
- There was high-grade evidence that tests for the detection of prothrombin G20210A have excellent analytic validity.
- There was high-grade evidence that most, but not all, clinical laboratories can test for FVL and prothrombin G20210A very accurately. There may be some laboratories that, for technical or administrative reasons, report inaccurate results.

## Key Question 3: Clinical Validity of Testing for FVL and/or Prothrombin G202010A

The next section of evidence describes the clinical validity of testing for these mutations. While Key Question 2 asked whether the mutations could be detected, Key Question 3 asked whether the detection of the mutations could predict patient-relevant outcomes (i.e., thrombosis).

### FVL and Recurrent Venous Thrombosis in Probands

We identified 22 articles that examined the rates of recurrent VTE in individuals with a history of thrombosis (the probands) and the FVL mutation (Table 8 and Appendix G, Evidence Tables 5–12). Eighteen were conducted in Europe14, 19, 108–123 and four in North America.124–127 As we required, all studies followed patients prospectively for the occurrence of VTE and objectively diagnosed venous thrombosis with radiographic testing. Most were prospective cohort studies, but six were cohorts nested within randomized controlled trials. Of these, five tested anticoagulation management strategies116, 119, 123–125 and one tested the effect of hormone replacement on acquired activated protein C resistance.114 Two articles were derived from the same cohort (the Physicians’ Health Study).126, 127 Two other studies came from a cohort of Austrian patients.14, 112 Total sample sizes for the studies ranged from 30 to 953 genotyped probands. Ages were variable; one study targeted patients under 40 years old.117 Follow-up ranged from a median of 0.5 years to over 8 years.

Table 8 Pooled results describing the risk of recurrent VTE for probands with VTE compared to probands without mutations

Mutation | Studies, N | Studies With Data Appropriate for the Pooled Odds Ratio, n | Individuals Contributing to the Pooled Odds Ratio^*^, n | Pooled Odds Ratio^†^ (95% CI)
Heterozygous FVL | 14 | 13^‡^ | 4730 | 1.56 (1.14–2.12)
Homozygous FVL | 9^‡^ | 8^‡^ | 2382 | 2.65 (1.18–5.97)
Unspecified FVL^§^ | 8 | 3 | 362 | 1.56 (0.75–3.25)
Double Heterozygous FVL and PT 20210A | 4 | 3 | 843 | 4.81 (0.50–46)
Heterozygous PT 20210A | 11^‡^ | 10^‡^ | 3636 | 1.45 (0.96–2.21)
Mixed PT 20210A | 7 | 4 | 1143 | 0.73 (0.37–1.44)
Homozygous PT 20210A | 2 | NA | NA | NA

* studies without comparison groups or having zero events in both arms are not included

† unadjusted odds ratios, relative to probands without mutations

‡ the count includes both arms of a study that reported results separately for drug- versus placebo-treated patients

§ unspecified means that heterozygous and homozygous individuals were not distinguished in the study CI = confidence interval; FVL = Factor V Leiden; NA = not applicable; PT 20210A = prothrombin G20210A; VTE = venous thromboembolism

Given our selective criteria for article inclusion, the study quality was generally high (Appendix G, Evidence Table 5). Some studies did not have a primary objective of quantifying the rates of thrombosis recurrence according to mutation status. Specifically, nine articles had different objectives, including evaluation of the prognostic value of other variables (such as D-dimer levels, positive family history of thrombosis, or sex),14, 19, 115, 118 assessing anticoagulation strategies,123, 124 examining the natural history of treated upper-extremity thrombosis,109 evaluating the relationship between mutation status and non-clinical hematologic variables,121 or assessing the impact of post-menopausal hormone replacement on resistance to activated protein C.114 Most studies described the outcomes separately for individuals who were homozygous and those who were heterozygous for FVL, but some combined homozygotes with heterozygotes when quantifying the number of recurrent events.14, 109–111, 115, 117, 119, 121, 122 Two studies did not include an FVL mutation-free comparison group.108, 122

The FVL mutation-free comparison groups varied in terms of whether other mutations or thrombophilic defects were included or excluded, as shown in Appendix G, Evidence Table 5. However, those studies that included individuals with other thrombotic defects in the control group generally also included them in the group of FVL-positive individuals. Many studies did not present descriptive data separately for individuals with and without FVL mutations. It was therefore not possible to confirm that those with and without the mutation were broadly similar. No study described interactions between FVL and other mutations (besides prothrombin G20210A). We saw no evidence of funding support that would have been likely to bias the results.

Heterozygous FVL in probands. Thirteen studies described event rates in probands who were heterozygous for FVL as well as probands without mutations (Table 9; Appendix G, Evidence Table 6).19, 111–114, 116, 118, 120, 123–127 Since two studies were derived from the same cohort,126, 127 we included only the more recent and larger of the two in our pooled analysis, so as to not count patients twice.126 One of the studies presented data separately for two treatment arms (ximelagatran extended prophylaxis versus placebo) and presented adequate data to allow us to analyze these two arms separately; therefore, we counted these arms as two different studies.123 In one article, the number of mutation-free patients was not given but could be calculated from percentages presented in the article; this calculation may have been subject to a small degree of rounding error.118 The number of probands heterozygous for FVL in these studies ranged from 19 to 161 (median = 83). The number of probands without this mutation ranged from 55 to 724 (median = 204). There were a total of 979 heterozygous individuals who suffered a total of 161 recurrent thrombotic events, and a total of 3751 mutation-free individuals who suffered a total of 473 thrombotic events. The pooled odds ratio for recurrent thrombosis was 1.56 (95 percent CI, 1.14–2.12) for FVL heterozygous individuals when compared to patients without the mutation (Figure 3). There was a fair amount of heterogeneity (I2 = 48 percent), but no significant evidence of publication bias. In our sensitivity analysis, in which we removed each study sequentially, the odds ratios were little changed. Annualized event rates in heterozygous individuals were reported in three studies and ranged from 3.1 to 7.5 percent.108, 113, 127

Figure 3 Odds ratios for VTE for probands with heterozygous FVL mutation, as compared to probands without the mutation*

*the size of the box is proportional to the study sample size; the confidence intervals (CI) for the pooled results are derived from a random effects model

Table 9 Pooled results describing the risk of VTE for family members of probands with VTE, comparing those with a mutation to those without a mutation

Mutation | Studies, N | Studies With Data Appropriate for the Pooled Odds Ratio, n | Individuals Contributing to the Pooled Odds Ratio^*^, n | Pooled Odds Ratio^†^ [95% CI]
Heterozygous FVL | 9 | 6 | 2,091 | 3.5 [2.5 to 5.0]
Homozygous FVL | 6 | 5 | 896 | 18 [7.8 to 40]
Mixed FVL | 6 | 6 | 3831 | 2.9 [1.8 to 4.8]
Double Heterozygous FVL and PT 20210A | 4 | 3 | 727 | 6.7 [2.9 to 15]
Mixed PT 20210A | 1 | NA | NA | NA
Homozygous PT 20210A | 1 | NA | NA | NA
Heterozygous PT 20210A | 3 | 3 | 291 | 1.9 [0.35 to 10]

* Studies without comparison groups or having zero events in both arms not included

† Unadjusted odds ratios, relative to family members without mutations

CI = confidence interval; FVL = Factor V Leiden; NA = not applicable; PT 20210A = prothrombin G20210A; VTE = venous thromboembolism

Homozygous FVL in probands. Seven studies described event rates in probands homozygous for FVL and also in those without mutations (Table 5; Appendix G, Evidence Table 7).19, 111, 114, 116, 123–125 One of the studies presented data separately for two treatment arms within one study (ximelagatran extended prophylaxis versus placebo), and we analyzed these arms separately as two different studies.123 The number of FVL-homozygous probands in these studies ranged from 1 to 11 (median = 6). The number of FVL-negative probands ranged from 55 to 469 (median = 360). There were a total of 49 homozygotes who suffered a total of 7 recurrent thrombotic events, and a total of 2333 mutation-free controls who suffered a total of 225 thrombotic events. The pooled odds ratio was 2.65 (95 percent CI, 1.18–5.97) (Figure 4). There was no evidence of significant heterogeneity (I2 = 0 percent). In our sensitivity analysis, in which we removed each study sequentially, the odds ratios changed little. One study specifically sought to determine whether FVL homozygosity carried a higher rate of recurrence than did FVL heterozygosity.108 This study did not include a control group without FVL. In this study, 5 of 32 individuals homozygous for the mutation (16 percent) developed recurrent thrombosis, and 12 of 108 individuals with heterozygosity developed recurrence (11 percent). This difference was not statistically significant, but the relative risk for recurrence was marginally significant after excluding from both groups those patients who also carried the prothrombin G20210A mutation (relative risk, 1.8; 95 percent CI, 1.0–6.2). The annualized event rate was reported for homozygotes in only one study, as 5.8 percent (95 percent CI, 4.9–7.4).108

Figure 4 Odds ratios for VTE for probands with homozygous FVL mutation, as compared to probands without the mutation*

*the size of the box is proportional to the study sample size; the confidence intervals (CI) for the pooled results were derived from a random effects model

Unspecified FVL in probands. The authors of eight articles combined the individuals who were heterozygous and those who were homozygous for FVL in their analyses,14, 109, 110, 115, 117, 119, 121, 122 without providing adequate detail in the text or tables to allow us to report the results separately for these individuals (Table 8; Appendix G, Evidence Table 8). Only three of these reported the number of events in the group with mutations as well as a group of probands without mutations, allowing for pooling.109, 119, 121 The number of probands with FVL in these studies ranged from 3 to 50, and the number of mutation-free individuals ranged from 24 to 138. There were 68 individuals with FVL who suffered a total of 12 events. Among 294 control patients, there were 46 events. The pooled odds ratio was very similar to that for heterozygotes, at 1.56 (95 percent CI, 0.75–3.25) (Figure 5). There was no evidence of heterogeneity (I2 = 0 percent). Among the studies that did not report the actual number of events, and therefore could not be included in our pooled analysis, four did test whether the FVL mutation was associated with recurrent thrombosis.14, 110, 115, 117 None of these individual analyses demonstrated that the mutation was a significant predictor of recurrent events. The reported hazard ratio (HR) or relative risk values ranged from 1.2–1.35. One study simply reported the results as non-significant without further quantification.115

Figure 5 Odds ratios for VTE for probands with unspecified FVL mutations, as compared to probands without the mutation*

*the size of the box is proportional to the study sample size; the confidence intervals (CI) for the pooled results were derived from a random effects model

We pooled these studies of unspecified zygosity with the studies of heterogeneous FVL, since we presumed that most of the unspecified individuals were indeed heterogeneous for the mutation. The pooled estimate from combining these 17 studies was an odds ratio of 1.61 (95 percent CI, 1.24 – 2.10), which is just slightly above the estimate for heterogenous FVL alone.

Individuals with an idiopathic index event. Patients with idiopathic events (unprovoked VTE) are often advised to take life-long anticoagulation. There is a great deal of interest in whether this patient population can be better stratified according to risk of recurrence. Among the studies that included only patients with idiopathic index thromboses112, 124, 125, 127 and the studies in which results were reported separately for individuals with idiopathic index events,119, 120 the pooled odds ratio for recurrence was 1.17 (95 percent CI, 0.63 – 2.18.) for individuals with FVL, as compared to individuals without. Only one of these studies was not exclusively composed of probands with heterogeneous FVL (the zygosity was unspecified).119 A single study described recurrence rates for individuals with FVL who had a clearly provoked VTE (non-idiopathic VTE), with an odds ratio of 6.5 (95 percent CI, 2.5 –18).120

Double (or compound) heterozygous (FVL plus the prothrombin G20210A mutation) probands. Three articles presented event rates in individuals having a FVL mutation as well as a prothrombin G20210A mutation and in mutation-free control patients (Table 8; Appendix G, Evidence Table 9).19, 120, 126 There were 10 doubly heterozygous individuals in all, 4 of whom suffered recurrent events. Among the mutation-free controls, there were 95 recurrent thromboses in 833 patients. The pooled odds ratio was 4.81 (95 percent CI, 0.50–46.3) (Figure 6). In one study, all three double heterozygotes developed recurrent thrombosis,126 requiring a continuity correction for calculating pooled odds ratios. The odds ratio was lower when this study was excluded during sensitivity testing analysis (odds ratio, 1.64; 95 percent CI, 0.25–11). Annual incidence rates were not reported in these studies.

Figure 6 Odds ratios for VTE for probands who were doubly heterozygous for the FVL and prothrombin G20210A mutations, as compared to probands without mutations*

*the size of the box is proportional to the study sample size; the confidence intervals (CI) for the pooled results are derived from a random effects model

Prothrombin G20210A and recurrent venous thrombosis in probands. We identified 18 articles that examined the rates of recurrent VTE in probands with the prothrombin G20210A mutation (Table 8; Appendix G, Evidence Table 10).14, 19, 109–112, 115–120, 122–126, 128 All of these studies were included in the 22 studies examining FVL (above), and therefore they generally shared common control groups with the FVL analyses. They also suffered from similar limitations, as discussed above in the section FVL and recurrent venous thrombosis in probands. These limitations included: a limited description of covariates, such as age and sex, in those with and without the mutation; combining individuals with homozygous and heterozygous mutations when reporting results; and, in some studies, not specifying the exact number of thrombotic events in each arm in the case of those with and without the mutation.

Heterozyous prothrombin G20210A in probands. Nine articles quantified event rates in the probands who were heterozygous for prothrombin G20210A and also in mutation-free probands (Table 8; Appendix G, Evidence Table 11).19, 113, 116, 118, 120, 123–126 One of the studies presented data separately for two treatment arms (ximelagatran extended prophylaxis versus placebo), and we analyzed these two arms separately.123 The number of probands with a heterozygous prothrombin G20210A mutation in these studies ranged from 3 to 58 (median = 26.5). The number of comparison individuals without the mutation ranged from 72 to 724 (median = 307). There were a total of 281 heterozygous individuals who suffered 38 recurrent thrombotic events, and a total of 3355 mutation-free individuals who suffered 385 thrombotic events. The pooled odds ratio was 1.45 (95 percent CI, 0.96–2.21) (Figure 7). There was little evidence of heterogeneity (I2 =8 percent), and no evidence of publication bias. In our sensitivity analysis, one study did have a major impact on the pooled odds ratio: This was the study that had an odds ratio of 4.0.^120^ Removal of this study from the meta-analysis decreased the pooled odds ratio to 1.30. Annual recurrence rates were reported in two studies and were 0 and 2.9 percent.113, 125 and a total of 3355 mutation-free individuals who suffered 385 thrombotic events. The pooled odds ratio was 1.45 (95 percent CI, 0.96–2.21) (Figure 7). There was little evidence of heterogeneity (I2 =8 percent), and no evidence of publication bias. In our sensitivity analysis, one study did have a major impact on the pooled odds ratio: This was the study that had an odds ratio of 4.0.^120^ Removal of this study from the meta-analysis decreased the pooled odds ratio to 1.30. Annual recurrence rates were reported in two studies and were 0 and 2.9 percent.113, 125

Figure 7 Odds ratios for VTE for probands who were heterozygous for prothrombin G20210A, as compared to probands without the mutation*

*the size of the box is proportional to the study sample size; the confidence intervals (CI) for the pooled results are derived from a random effects model

Unspecified prothrombin G20210A in probands. The authors of seven articles combined individuals who were heterozygous and those who were homozygous for prothrombin G20210A14, 109–111, 115, 119, 128 (Table 8; Appendix G, Evidence Table X). Four of these articles described event rates in this combined prothrombin G20210A group as well as in a group of mutation-free probands.109, 111, 119, 128 In our pooled analysis, there were a total of 86 individuals with the prothrombin G20210A mutation who had 10 recurrent events, and 1057 patients without the mutation who suffered 158 recurrent events. The pooled odds ratio was 0.73 (95 percent CI, 0.37–1.44) (Figure 8). There was no evidence of significant heterogeneity (I2 = 0 percent). Relative risk or HR values were reported in five of the studies14, 110, 111, 115, 128 and ranged from 0.7 to 2.1. Of note, three of the studies that presented relative risk or HR were not included in the pooled analysis, since the specific number of events was not reported.14, 110, 115 Two of these studies reported adjusted relative risks that were significantly different from 1.0, with adjusted relative risk estimates of 2.1 in both cases.14, 115 The annual incident rate of recurrent thrombosis was reported in only one study, at 1.9 percent.111

Figure 8 Odds ratios for VTE for probands with unspecified prothrombin G20210A mutation, as compared to probands without the mutation*

*The size of the box is proportional to the study sample size; the confidence intervals (CI) for the pooled results are derived from a random effects model

Since probands with unspecified prothrombin G20210A mutations are almost certainly heterozygous for the mutation, given the rarity of homozygous prothrombin G202010A, we pooled these studies with the studies of probands known to be heterozygous. The combined odds ratio was 1.23 (95 percent CI, 0.87–1.7).

Homozygous prothrombin G20210A in probands. Only two articles quantified event rates in individuals homozygous for prothrombin G20210A and in mutation-free probands.123, 125 There were a total of only three homozygous individuals in these studies, and none of them developed recurrent thrombosis.

### Summary of the Evidence for Key Question 3 (Probands)

Based upon our review of the published literature, we can summarize the evidence regarding the clinical validity of testing for FVL and prothrombin G20210A as follows:

- There was moderate-grade evidence that homozygosity for FVL in probands is predictive of recurrent VTE.
- There was moderate-grade evidence that heterozygosity for FVL in probands is predictive of recurrent VTE.
- Homozygosity for prothrombin G20210A is a rare genotype, and its association with recurrent venous thrombosis in probands is currently unknown, because of a lack of sufficient evidence.
- There was only low-grade evidence that heterozygosity for prothrombin G20201A in probands is not predictive of recurrent VTE.
- There is insufficient evidence to allow us to draw any conclusions about double heterozygosity (FVL and prothrombin G20210A) in probands.

### FVL and Prothrombin G20210A and Venous Thrombosis in Family Members

We identified 18 articles that evaluated venous thrombosis in family members of probands. All were conducted in Europe, with the majority in the Netherlands or France (Table 9, Appendix G, Evidence Tables 13–17). Five studies were prospective or included a prospective component,129–133 and the rest were retrospective cohort studies. One was a letter to the editor.133 The smallest study enrolled 13 people from a single family;134 the largest enrolled 1,093 family members.26 Inclusion criteria were not always stated, except for requiring that subjects be family members of probands with VTE. Three of the five prospective studies had scheduled clinical surveillance for VTE events, either annually or biannually.129, 130, 132 The individuals in the mutation-free comparison groups described below were generally the same in each of the comparisons within a given study. Only two studies explicitly excluded family members with prothrombin G20210A in their calculation of the odds ratio associated with FVL positivity.26, 130

Study quality was mixed (see Appendix G, Evidence Table 13). To some extent, it was challenging to assess the quality of these studies, since they were not necessarily designed to answer our question (e.g., the clinical validity question was secondary to their primary aims). In our quality assessment, we focused mostly on biases that might result from the sampling scheme. For the prospective studies, we also were attentive to the description of losses to follow-up and the percentage of participants lost; this was only relevant to five of these studies. Three described the number lost, and it was low;129–131 the others provided no description.132, 133 Studies varied greatly in terms of the degree to which they described the population from which the participants came. Since these were family members of probands, studies with adequate description generally described the source of the probands, and then provided a description of the recruitment process used to enroll family members. Several of the studies had very little description of the inclusion and exclusion criteria for the family members.133, 135–137 Even among those that had explicit inclusion criteria, not all uniformly provided a detailed description of the enrolled participants. Even age and sex were inconsistently described. The majority of these studies were published before journals began requiring disclosure of funding sources and potential conflicts of interest. More studies than not, however, did report on the source of funding; we considered these sources of funding to be unlikely to bias the results, since most of the reported funding was from governmental grant support.

Heterozygous FVL in family members. Nine studies described results for people heterozygous for FVL (Table 9, Appendix G, Evidence Tables 14 and 15).129, 130, 132, 134, 137–141, although one of these included a single person homozygous for the mutation among the 91 studied.138 Two of the studies did not report on a comparison group without mutation.129, 141 The seven studies with comparison groups enrolled between 5 and 299 affected individuals, for a total of 1,066 heterozygous family members. We show the rates of events among the affected family members, as compared to the rates of events among 940 unaffected family members (Appendix G, Evidence Table 15). The odds ratios across these studies were quite comparable except for the one small study by Simioni, in 2000, in which there were no events among the eight heterozygous individuals.137

The pooled odds ratio was 3.49 (95 percent CI, 2.46 to 4.96), with very little heterogeneity between studies (I2= 4 percent) (Figure 9). The small study by Rintelen contributed little to the pooled estimate.

Figure 9 Odds ratios for VTE for family members with a heterozygous FVL mutation, as compared to family members without the mutation*

*the size of the box is proportional to the study sample size; the confidence intervals (CI) for the pooled results are derived from a random effects model

Three of these studies reported person-years of observation to allow calculation of the annual rate of VTE events.129, 130, 132 Our sensitivity analysis, in which we removed each study sequentially, demonstrated that removal of the study by Couturaud et al.132 raised the pooled odds ratio to close to 4.0, although the CI values overlapped the pooled odds ratio when that study was included. The annualized event rate among heterozygous individuals in this study was 0.36 percent (95 percent CI, 0.24 to 0.49), which is lower than those in the other two studies in which rates were reported.129, 130 It is not apparent from either the inclusion criteria or the patient characteristics why the rates were lower in this study, which was of adequate quality. The event rates in the mutation-free groups were fairly comparable across the three studies. There was no evidence of important publication bias.

Homozygous FVL in family members. Six studies described results for 48 people homozygous for FVL130, 132, 134, 137, 139, 140. The annualized rates were given in only three studies and are shown in Table 9, Appendix G, Evidence Tables 14 and 15.^129, 130, 132^ The odds of events were compared to the odds for 850 family members without mutations (Figure 9). The pooled odds ratio was 18 (95 percent CI, 7.8 to 40), with very little heterogeneity between studies (I2=0 percent) (Figure 10). One small study was excluded from pooling because it had no events in either arm and only a single individual in each arm.134 One study, a French study by Couturaud et al.,139 was particularly influential in raising the odds ratio. Removal of that study in the sensitivity analysis resulted in a pooled odds ratio of roughly 16, with an upper limit of the CI that did not reach 18. It is not apparent why the event rate was so high in this French study (five of the six individuals with homozygosity had VTE events). The annualized rate was not described for their mutation-free comparison group. There was no evidence of important publication bias for this comparison.

Figure 10 Odds ratios for VTE for family members with homozygous FVL mutation, as compared to family members without the mutation*

*the size of the box is proportional to the study sample size; the confidence intervals (CI) for the pooled results are derived from a random effects model

Mixed or unspecified FVL in family members. Nine studies reported the results from an unspecified group of homozygous and heterozygous individuals (Table 9, Appendix G, Evidence Tables 14 and 15).26, 131–133, 135, 136, 140, 142, 143 Three of these studies also described the results separately for these groups, so we will not discuss these composite groups here.26, 132, 140 The odds ratios for each study as well as the pooled odds ratio are given in Figure 11. The pooled odds ratio was 2.9 (95 percent CI, 1.8 to 4.8), with little heterogeneity between studies (I2=4 percent). One large study was particularly influential.142 The odds ratio of this study was 5.2; when it was removed from pooling, the aggregated odds ratio dropped to close to 2.0, with the upper limit of the CI extending only to 2.8. This influential study involved 1,437 family members from nine European countries and was part of the European Prospective Cohort on Thrombophilia (EPCOT) study of familial thrombophilia. Thirteen of the 225 family members with FVL were homozygous for the mutation. The event rate in members without mutations was quite low, at 0.03 percent (95 percent CI, 0.02 to 0.05). The prospective portion of the EPCOT study described very few VTE events among the family members with FVL, with an odds ratio of only 0.92 and wide confidence intervals (95 percent CI, 0.11 to 7.5).131

Figure 11 Odds ratios for VTE for family members with an unspecified FVL mutation, as compared to family members without the mutation*

*The size of the box is proportional to the study sample size; the confidence intervals (CI) for the pooled results are derived from a random effects model

Family members doubly heterozygous for FVL and prothrombin G20201A. Four studies described VTE events in a total of 59 doubly heterozygous individuals (Table 9, Appendix G, Evidence Tables 14 and 15).26, 132, 134, 137 These individuals were compared to a total of 674 individuals without mutations. The very small study134 observed no events in either arm. The odds ratios for each study as well as the pooled odds ratio are given in Figure 12. The pooled odds ratio was 6.7 (95 percent CI, 2.9 to 16), with very little heterogeneity between studies (I2=0 percent). The odds ratio associated with double heterozygosity in the large study by Martinelli et al. was higher than in the other two studies (odds ratio, 8.0; 95 percent CI, 2.8 to 23). This difference may be partially explained by the low rate of events in their study among the family members without mutations. The rate of events in the mutation-free group was 0.06 percent per year, whereas in most studies it was closer to 0.1 percent per year. In the case of this comparison, there may have been some degree of publication bias, given the paucity of small studies reporting large effect sizes (high odds ratios).

Figure 12 Odds ratios for VTE for family members with double heterozygous mutations, as compared to family members without mutations*

*The size of the box is proportional to the study sample size; the confidence intervals (CI) for the pooled results are derived from a random effects model

Prothrombin G20210A and venous thrombosis in family members. Five studies evaluated prothrombin G20210A and venous thrombosis in family members of probands.26, 132, 134, 137, 144 As mentioned above, all five studies were conducted in Europe. Only one of these studies was not described above in the discussion of FVL.144 This was a small study of adequate quality conducted in Italy that exclusively investigated outcomes from heterozygosity for prothrombin G20210A. This earliest study, by Castaman, had rigorous inclusion criteria and excluded women on oral contraceptive or hormonal therapies.144 Similarly, Martinelli et al. excluded people with malignancies or known autoimmune disease.26

Homozygous prothrombin G20210A in family members. Only a single study described a single patient who was homozygous for this mutation (Table 9, Appendix G, Evidence Tables 16 and 17).137 This patient was identified among 44 family members from four families and had no reported VTE events.

Heterozygous prothrombin G20210A in family members. Family members who were heterozygous for this mutation were compared to family members without the mutation in three studies (Table 9, Appendix G, Evidence Tables 16 and 17).132, 137, 144 In one study, an age-adjusted relative rate of events of 3.4 (95 percent CI, 0.2–56) was reported, when compared to family members without mutation.144 The other studies were very small, with one event in eight patients in one study137 and no events in six people in the other.132 Pooling these small studies yielded an odds ratio for VTE events of 1.89 (95 percent CI, 0.35–10), with an I2 of 0 percent, suggesting that family members who are heterozygous for this mutation do not have an elevated risk of thrombosis (Figure 13).

Figure 13 Odds ratios for VTE for family members with heterozygous prothrombin G20210A, as compared to family members without the mutation*

*The size of the box is proportional to the study sample size; the confidence intervals (CI) for the pooled results are derived from a random effects model

The doubly heterozygous individuals were described above in the discussion of FVL. The risk of VTE events was notably high for doubly heterozygous individuals.

### Association of FVL and Prothrombin G20210A With Venous Thrombosis During Pregnancy and the Postpartum Period

Testing asymptomatic family members for the FVL and prothrombin G20210A mutations would be important if the mutations raise the risk of venous thrombosis and if other risk factors can be modified or prophylactic interventions can be employed to lower the risk. A particularly important time with regard to risk is pregnancy and the postpartum period. These are high-risk times for VTE because hormonal and mechanical changes shift the balance in favor of hypercoaguability.145

Several of our included articles described the experience of family members of probands during their pregnancies. Here we report the results of studies that quantified the risk of VTE associated with FVL and prothrombin G20210A specifically during pregnancy and the postpartum period for these family members of patients with VTE. Occasionally these studies included probands and evaluation of their subsequent pregnancies; this situation was rare, and we excluded these probands from our analyses.

We identified four articles that specifically addressed the risk of venous thrombosis attributable to FVL and prothrombin G20210A during the pregnancies of family members,146–149 and one additional study that included useable pregnancy data.132 All were retrospective cohort studies conducted in Europe; one included a prospective component132 (Appendix G, Evidence Tables 18 and 19). Two explicitly excluded women who had had a venous thrombosis prior to pregnancy.147, 149

Although not explicitly stated, we believe that the two studies by Martinelli et al. include some of the same women, so we did not extract data about the women who were homozygous for FVL from the more recent of the two studies.146, 149 The mutation-free groups described in these two studies may also include many of the same women. We show the results in Appendix G, Evidence Tables 18 and 19. The odds ratios compare the odds of a VTE event per pregnancy across two groups, with the reference group being women with neither FVL nor the prothrombin G20210A mutation.

Two studies evaluated the risk associated with homozygous FVL.146,147 The number of pregnant women with homozygous FVL was small, with only nine in one study146 and six in the other,147 and a total of 33 pregnancies among them. The odds ratios for venous thrombosis were very high, although with wide CIs, suggesting that homozygosity for FVL is associated with venous thrombosis in the pregnancy or post-partum periods.

The odds ratios associated with heterozygous FVL were close to 1.0 and quite similar in the two studies reporting this outcome. The rates of events were low, at 2.5 percent per pregnancy (95 percent CI, 0.9–5.4)147 and 1.5 percent per pregnancy (95 percent CI, 0.5–4.3).149 Two studies evaluated the risk associated with heterozygosity for the prothrombin G20210A mutation. A total of 247 women with this mutation were studied. The rates of VTE were low, at 0.3 percent per pregnancy (95 percent CI, 0.1 to 1.6)148 and 1 percent per pregnancy (95 percent CI, 0.2–3.6).149 These odds ratios were also close to 1.0.

Individuals who were doubly heterozygous were evaluated in two studies.147,149 The larger of the two studies reported an odds ratio that was quite similar to the odds ratios associated with heterozygosity of either of the two mutations.149 The small study (five doubly heterozygous women with pregnancies) reported an odds ratio comparable to that seen in the women with homozygosity for FVL.147 The study with a prospective component only reported the results for a group of women with unspecified FVL that may have included some women who were homozygous for the mutation. The number of pregnancies was not described, only the number of women with pregnancies. The risk ratio for venous thrombosis in women with FVL as compared to those without was 2.9 (95 percent CI, 0.96–8.4).

### Age and VTE Among Family Members With Mutations

We sought to examine whether the risk attributable to the mutations varied with age. Few studies reported results stratified by age. None of the studies of prothrombin G20210A described the results according to age. Three studies examining the risk from the FVL mutation described age-specific rates of events.138,140,143 One additional study described the age of the individuals at the time of their first thromboses in the family members with and without mutations.139 The mean age at thrombosis was 40 years in the family members without a mutation, 34 years in people who were heterozygous for FVL, and 21 years in homozygous individuals. The difference was not statistically significant when heterozygous and mutation-free individuals were compared (p=0.07), but it was significant when homozygous and mutation-free individuals were compared (p=0.009).

Middledorp et al. described age-specific relative rates of events for a group (homozygous, heterozygous, double heterozygous) with FVL mutation, as compared to family members without mutations (Appendix G, Evidence Tables 14 and 15). The relative risk posed by the mutation was highest in the youngest patients, aged 15 to 30 (relative rate of approximately 15) and was lower and more comparable across the older age strata.140 Similarly, Simioni et al. described age-specific rates in a group of family members with unspecified FVL mutations.143 The relative rate in the youngest age group was much lower than that reported in the Middeldorp study. Similarly, Lensen et al. described age-specific rates among heterozygous individuals that were not importantly different across age strata.138

The study by Lensen et al. presented a relative hazard value from a Cox model across the lifetime of these heterozygous relatives, as compared to the mutation-free relatives. The relative hazard was 3.4 (95 percent CI, 1.3–9.2), which is remarkably similar to the odds ratio we calculated for the pooled studies of heterozygous individuals, 3.42 (95 percent CI, 2.40 to 4.89). Another study reported an HR (adjusted for age, sex and other factor deficiencies).26 The relative hazard for the FVL heterozygous individuals was 2.7 (95 percent CI, 1.4–18) and 6.5 (95 percent CI, 2.4–18) for the doubly heterozygous family members. This study also reported an HR for individuals with an isolated prothrombin G20210A mutation (Appendix G, Evidence Tables 16 and 17).

### Other High-risk Periods

In addition to analyzing the pregnancy and postpartum periods, we sought information on whether FVL or prothrombin G20210A additively or multiplicatively raised the risk of VTE during other high-risk periods, such as following surgery or during the use of hormonal therapy. Very few studies reported event rates stratified by high-risk periods,135, 143 and we were unable to draw any conclusions regarding such periods.

### Summary of the Evidence for Key Question 3 (Family Members)

The literature supported the following conclusions about the clinical validity of testing for FVL and prothrombin G20210A:

- There was high-grade evidence that homozygosity for FVL in family members is predictive of VTE.
- There was moderate-grade evidence that heterozygosity for FVL in family members is predictive of VTE.
- The evidence was insufficient to allow us to draw any conclusions about the predictive value of heterozygosity for prothrombin G20201A in family members.
- There was low-grade evidence that double heterozygosity (for FVL and prothrombin G20210A) in family members is predictive of VTE.
- There was low-grade evidence that homozygosity for FVL in pregnant family members is predictive of VTE.
- The evidence was insufficient to allow us to draw any conclusions about the predictive value of heterozygosity for FVL in pregnant family members.
- Homozygosity for prothrombin G20210A is a rare genotype, and its association with recurrent VTE in family members is unknown, because of the lack of sufficient evidence.
- The evidence was insufficient to allow us to draw any conclusions about the predictive value of heterozygosity for prothrombin G20210A in pregnant family members.
- The evidence was insufficient to allow us to draw any conclusions about the predictive value of double heterozygosity for FLV and prothrombin G20210A in pregnant family members.

## Key Question 4 Clinical Utility of Testing for FVL and/or Prothrombin G202010A

We identified 10 studies addressing the clinical utility of testing for these mutations. The studies varied substantially in their methodology and design, sources of the participants, geographical locations, and outcomes. We summarize our findings, including our assessment of the quality of these studies, according to the four main sub-questions of KQ4 (Tables 10–12).

Table 10 Four studies examining the effect on VTE-related outcomes of changes in therapy based on testing for FVL or prothrombin G20210A

Author, year | Type of Study | Population | Sample Size | Outcome of Interest | Key Conclusions
Ridker, 2003^151^ | Randomized controlled trial | - FVL or PT 20210A (pooled); - Prior unprovoked VTE; - Had 3 months of uninterrupted warfarin; - United States-based study; - Age range 46–65; - 53% males; - Mean follow-up 2.1 years (maximum 4.3) | 508 participants: 253 assigned to placebo (26.6% FVL carriers, 4.8% PT G20210A carriers), 255 assigned to low-intensity warfarin (22.0% FVL carriers, 4.7% PT G20210A carriers) | - VTE recurrence while treated with low-intensity warfarin; - VTE recurrence rate among carriers | Low-intensity warfarin reduces recurrence in non-carriers by 58% (HR, 0.42; 95% CI, 0.20–0.86) and it reduces recurrence in carriers by 75% (HR, 0.25; 95% CI, 0.07–0.87).
Kearon, 2008^125^ | Cohort analysis nested within randomized controlled trial | - FVL or PT 20210A; - Prior VTE; - Had 3 months of uninterrupted warfarin; - Canada-based study; - Mean age, 57 (SD, 15); - 54–58% males; - Mean follow-up 2.3 years | 661 participants (pooled): 337 assigned to low-intensity warfarin (91 FVL, 32 PT G20210A), 324 assigned to conventional-intensity warfarin (80 FVL, 28 PT 20210A) | - VTE recurrence while treated with either low- intensity or conventional- intensity warfarin; - VTE recurrence rate among carriers, as compared to non-carriers | Conventional-intensity warfarin reduces recurrence when compared to low-intensity warfarin. The rate of recurrence was 1.5% per patient-year among the patients allocated to low- intensity therapy and 0.4% per patient-year among the patients allocated to conventional-intensity therapy (HR, 3.7; 95% CI, 1.03 to 13.2). The absolute rate of recurrence for FVL carriers in combined groups was 0.8% per patient-year (0.2, 2.2) and was less than in those without a defect (HR 0.7; 95% CI, 0.2–2.6).
Wahlander, 2006^123^ | Cohort analysis nested within randomized controlled trial | - FVL or PT 20210A; - Prior VTE; - Had completed 6 months of uninterrupted warfarin; - European-based study; - 18-month study period | 1223 participants: 612 oral ximelagatran (111 FVL, 27 PT 20210A), 611 placebo (125 FVL, 27 PT G20210A) | - VTE recurrence while treated with ximelagatran; - VTE recurrence rate among carriers | Oral ximelagatran reduces recurrence in non-carriers as well as FVL carriers (Figure 2, HR not presented).
Vossen, 2005^122^ | Prospective cohort | - FVL or combined FVL-PT 20210A; - Prior VTE; - European-based study; - Age range 14–78; - 35–48% males; - Followed for 1710 person-years (mean, 5.6; range, 1–7) | 304 participants: 124 on long-term anticoagulation (13 FVL, 1 combined FVL- PT 20210A), 180 not on long-term anticoagulation (79 FVL, 7 combined FVL- PT G2021A) | - VTE recurrence while treated with long-term anticoagulation; - VTE recurrence rate among carriers | Long-term anticoagulation reduces recurrence in non-carriers. The rate of recurrence was 1.1% per year among the patients on long-term anticoagulation and 5.0% per year among the patients not on long-term anticoagulation. The rate of recurrence for FVL carriers not on long-term anticoagulation was 3.5%. There were no events in the group on long-term anticoagulation.

CI = confidence interval; FVL = Factor V Leiden; HR = hazard ratio; PT G20210A = prothrombin G20210A; SD = standard deviation; VTE = venous thromboembolism

Table 11 Studies examining the effect of FVL and prothrombin G20210A testing on non-VTE-related outcomes

Author, year | Type of Study | Population | Sample Size | Outcome of Interest | Key Conclusions
Bank, 2004^157^ | Qualitative, structured interview | - Asymptomatic first-degree relatives of probands; - Tested for FVL; - In the Netherlands; - Age, 26–56 years; - 53% males | 17 participants (65% response rate) | Overall experience with testing; effects of testing on daily life | - For most, testing not stressful (all received written information about FVL testing); - More concern about relatives’ health than their own; - No changes in daily life for the majority of participants
Teutsch, 2008^156^ and Saukko, 2007^155^ | Qualitative, structured interview | - Probands or relatives referred for FVL testing; - In the United Kingdom; - 12% males | 42 participants (43% response rate) | Understanding of testing process and implications of results on daily life | - Most did not consider FVL testing to be different than other tests ordered by clinician; - Less understanding among those of lower socio-economic status; - Most did not change daily routine as a result of testing
Kaptien, 2008^154^ | Cross-sectional survey | - Probands and relatives recruited from EPCOT study; - Tested for FVL, AT, PC, or PS deficiency; - In Europe (multiple countries); - Age, 26–87 years; - 46% males | 174 participants (78% response rate) | VTE risk perception and disease-related worry | - Increased risk perception and worry among those with prior VTE; - Level of worry among those with FVL lower than in those with AT and similar to those with PS, PC
Heshka, 2008^153^ | Cross-sectional survey | - Asymptomatic first-degree relatives of probands, not on long-term anticoagulation; - Tested for FVL or PT 20210A; - In Canada; - Age, 21–78 years; - 38% males | 70 participants: 44 carriers (86% response rate) 26 non-carriers (55% response rate) | Perception of VTE risk and changes in behavior following FVL or PT 20210A testing | - No significant differences in recognition of VTE risk factors between carriers and non-carriers, despite counseling; - Behavior changes in response to testing were uncommon in both groups

AT = antithrombin deficiency; EPCOT = European Prospective Cohort on Thrombophilia; FVL = Factor V Leiden; PC = protein C deficiency; PS = protein S deficiency; PT 20210A = prothrombin G20210A; VTE = venous thromboembolism

Table 12 Summary of studies evaluating the cost-effectiveness of testing for FVL and/or prothrombin G20210A mutations

Study | Design | Interventions Compared | Population | Outcomes | Results^*^ | Quality Deficits
Sarasin, 1998^164^ | Decision analysis with a Markov model | Extending oral anticoagulation up to 5 years vs. 3 months oral anticoagulation for carriers and non-carriers of FVL | Probands: Individuals having had a DVT and 3 months of anticoagulation | DVT/PE prevented, major bleeding induced | For those with FVL, for all durations of anticoagulation, the number of major iatrogenic bleeding episodes exceeded the number of PEs prevented, although the number of bleeding episodes was far less than the number of DVTs averted, by a ratio of 1:3 after 1 year, and decreased with longer duration. If the bleeding risk was <2.5% per year, continued anticoagulation was preferred. | Structure – the time horizon of this model may not have captured the full treatment effect, the rejection of quality weights for health states made comparison of the outcomes difficult, and the Markov cycle length was unspecified; Data – the authors did not address methodological or structural uncertainty; Consistency – internal and external consistency were not discussed
Marchetti, 2000^163^ | CEA, decision analysis with a Markov model | Screening for FVL with 2 years of warfarin vs. no screening with 6 months of warfarin | Probands: 60-year-old males with a personal history of VTE | Costs, QALYs, DVT/PE averted, major bleeding induced, life years | Testing for FVL, followed by extended anticoagulation, was cost-effective ($15,451/QALY). ICER > $50,000/QALY for individuals with high bleeding risk (>0.34% per year), low VTE recurrence rate (<9% in first 2 years), low anticoagulation efficacy (<74%), or low anticoagulation compliance (<94%). | Structure – a single anticoagulant duration modeled without discussion of alternatives or justification of their exclusion; Data – half-cycle correction not discussed, structural uncertainty not addressed; Consistency – internal consistency not discussed.
Marchetti, 2001^162^ | CEA, decision analysis with a Markov model | Screening for double heterozygosity with 2 years of warfarin vs. no screening and 6 months of warfarin | Probands: 60-year-old males with personal history of VTE | Costs, QALYs, DVT/PE averted, major bleeding induced, life years | Testing for both mutations, with subsequent extended anticoagulation for double heterozygous individuals, was cost-effective (ICER $15,959/QALY). ICER > $50,000/QALY for individuals with high bleeding risk (>1.6% in 6 months), low double-heterozygote prevalence (<1.4%), low PE mortality (<10%), or low anticoagulation efficacy (<65%). | Structure – a single anticoagulant duration modeled without discussion of alternatives or justification of their exclusion; Data – half-cycle correction not discussed, structural uncertainty not addressed; Consistency – internal consistency not discussed.
Clark, 2002^160^ | CEA, prospective cohort | Universal FVL screening or selective FVL screening based on personal or family history of VTE (prophylactic enoxaparin for FVL carriers in both cases) vs. no screening | Pregnant women attending antenatal care | Costs, pregnancy-related vascular complications | $15,173/vascular complication prevented for selective screening with prophylactic anticoagulation relative to no screening; $26,744/vascular complication prevented for universal screening with prophylactic anticoagulation relative to no screening (not considered cost-effective). ICER for selective screening with 100% effective anticoagulant prophylaxis was $5758/vascular complication averted relative to no screening. | Structure – model not described; scope, outcomes, and time horizon not justified; Data – assumption of prophylactic efficacy not discussed or justified, no discussion of treatment alternatives or quality of life weighting, no assessment of uncertainty beyond the parameter of anticoagulant efficacy; Consistency – no assessment of internal or external consistency
Eckman, 2002^161^ | CEA, decision analysis with a Markov model | Screening for FVL with warfarin for 3 years or lifelong vs. no screening and 6 months of warfarin | Probands: 35-year-old females with a personal history of VTE | Costs, QALYs | Testing and treating with 3 years of anticoagulation dominated (in base case); $20,937/QALY for testing and treating with lifelong anticoagulation relative to no screening with 6 months anticoagulation, with a constant VTE rate at 7.3%/year. Model very sensitive to rate of recurrent VTE. | Structure – societal perspective claimed, though only direct healthcare costs modeled; Markov cycle length not explicitly stated; Data – half-cycle correction was not mentioned, quality of life weights not justified, only costs were discounted, structural uncertainty not addressed; Consistency – internal consistency not addressed
Auerbach, 2004^159^ | CEA, decision analysis with a Markov model | Hypercoagulability testing with anticoagulation for 6 months to indefinite depending on results vs. no testing with anticoagulation for 6 months to indefinite | Probands: 40-year-old following a DVT and 6 months of anticoagulation | Costs, QALYs | $13,365/QALY for testing followed by 24 months anticoagulation for positive individuals relative to no testing followed by 24 months anticoagulation for all individuals (base case). Cost-effective to test for disorders conferring a RR of recurrent VTE > 1.25 with a prevalence > 5%, followed by 2 years of anticoagulation for 2 years (or indefinitely if the relative risk exceeds 6). This would include testing for FVL and for double heterozygosity. | Structure – societal perspective stated but only direct costs incorporated, Markov cycle length unspecified; Data – half-cycle correction not mentioned, utility weights not justified, structural uncertainty not addressed; Consistency – internal consistency not discussed
Wu, 2006^158^ | CEA, decision analysis model | Universal thrombophilia screening vs. selective screening based on personal and family VTE history vs. no screening | (1) women prior to OC use, (2) women prior to HRT, (3) pregnant women at 6 weeks of gestation, (4) patients prior to major orthopedic surgery | Costs, adverse clinical events prevented | Selective screening relative to no screening: $136,604/complication prevented in cohort 1, $4,226/complication prevented in cohort 2, $140,344/complication prevented in cohort 3 (not cost-effective), $15,780/complication prevented in cohort 4. | Structure – the short time horizon of the model may not have captured the full treatment effects, the absence of quality weights makes comparing the health outcomes difficult, and the pregnancy cohort included an aggregate outcome that is difficult to interpret; Data – structural uncertainty not addressed; Consistency – internal consistency not discussed

* Monetary values converted into U.S. dollars (2007)

CEA = cost-effectiveness analysis; DVT = deep venous thrombosis; FVL = Factor V Leiden; ICER = incremental cost-effectiveness ratio; HRT = hormone replacement therapy; OC = oral contraceptive; PE = pulmonary embolism; QALYs = quality-adjusted life years; RR = relative risk; VTE = venous thromboembolism

### Effect of Testing on Clinicians’ Management (KQ 4a)

We found a single study addressing how physicians’ management decisions are affected by FVL testing (Appendix G, Evidence Table 21).150 Rodger et al surveyed 662 Canadian obstetrical care providers (65 percent of whom were obstetricians, 28 percent family practitioners, and 5 percent perinatologists), about their management recommendations in response to four clinical scenarios involving pregnant women with a history of FVL. The survey asked whether the practitioners would recommend peripartum thromboprophylaxis and whether they would refer the patient to a hematologist or to another specialist. The survey response rate was 46 percent (1,448 members of the Society of Obstetricians and Gynecologists of Canada had been invited to participate); 57 percent of the respondents were male. For scenarios involving asymptomatic women, the recommendation for thromboprophylaxis almost doubled, from 26–34 percent to 58 percent, if the patient was described as having a family history of VTE. For scenarios involving symptomatic women, 60–68 percent of clinicians recommended prophylaxis for women with recurrent fetal loss, and 83–84 percent of clinicians recommended it for women with a personal history of VTE. Uncertainty was prevalent regarding the use of prophylaxis: 14 percent of clinicians were unsure as to whether or not to recommend prophylaxis when the patient had a history of prior VTE, and 29 percent were unsure in cases in which the patient had a family history of VTE or recurrent fetal loss. More than 80 percent of clinicians would refer a pregnant woman with a history of FVL to a specialist. This study suggests a high degree of uncertainty regarding the management of pregnant patients with a history of FVL, with clinicians reporting a preference to recommend prophylaxis and referral, particularly in cases of symptomatic women.

### Effect of Testing and Resultant Mnagement on VTE-related Otcomes (KQ 4b)

There were four studies yielding VTE recurrence rates among probands with FVL or prothrombin G20210A during anticoagulation therapy (Table 10, Appendix G, Evidence Tables 22–24).122,123,125,151 Each was a subgroup analysis; three involved individuals participating in randomized controlled trials,123,125,151 while the fourth was nested within a prospective cohort study.122 Three of the four studies included participants with FVL or prothrombin G20210A,123, 125,151 while the fourth addressed only FVL.122 Two studies investigated the effect of warfarin on recurrence rates,125,151 one the effect of ximelagatran,123 and one did not specify the treatment that patients received.122 None of these studies was designed to examine how testing effects changes in management or whether choosing treatment based on test results alters outcomes. As required for inclusion in this report, all index events and recurrences were objectively documented. There were quality flaws across the studies, including inadequate description of how patients were recruited, raising the possibility of selection bias (Appendix G, Evidence Table 20). Only one of the studies described the number of patients lost to follow-up.122 Although some of the studies had stringent inclusion and exclusion criteria, for the most part these were the criteria for safely using these drugs. Ridker et al assessed thromboembolism recurrence rates among individuals with FVL or prothrombin G20210A who received either a low-intensity warfarin regimen (international normalized ratio [INR] target between 1.5 and 2.0) or placebo151 (Table 10). Each participant had experienced a prior unprovoked VTE and had completed at least 3 months of uninterrupted treatment with warfarin. The patients randomized to the placebo and treatment groups had similar demographic and clinical characteristics. Of 77 patients with FVL or prothrombin G20210A in the placebo group, 14 had recurrences (8.6 events per 100 person-years), as compared to 3 of 66 such patients assigned to the low-intensity warfarin group (2.2 events per 100 person-years). Low-intensity warfarin reduced the rate of recurrence among thrombophilic patients by 75 percent (HR, 0.25; 95 percent CI, 0.07 to 0.85). This risk reduction, however, was not significantly different than the 58 percent reduction seen in patients without either mutation (HR, 0.42; 95 percent CI, 0.20 to 0.86; p-value for the interaction, 0.51). These results suggest that low-intensity warfarin significantly decreases the rate of recurrence of VTE in patients with FVL or prothrombin G20210A; however, this protective effect was not different than that observed for individuals without the mutations.

Kearon et al asked whether VTE recurrence rates differed among patients with and without FVL or prothrombin G20210A who were receiving either low-intensity (INR goal, 1.5–2.0) or conventional (INR goal, 2.0–3.0) warfarin therapy.125 All patients were participants in the Extended Low-intensity Anticoagulation for Unprovoked Thromboembolism (ELATE) trial and were separately invited to participate in this study. Among 171 patients with FVL, three had recurrences. No recurrences were seen in the 60 patients with prothrombin G20210A. The recurrence rate for patients with FVL while receiving low- or conventional-intensity warfarin therapy was 0.8 percent per year (95 percent CI, 0.2 to 2.2). This rate was not statistically different than the rate among those participants without FVL (HR, 0.7; 95 percent CI, 0.2 to 2.6). The HR for recurrent VTE in the low-intensity warfarin group as compared to the conventional-intensity group was 2.7 among those with thrombophilia (not just FVL or prothrombin G20210A; 95 percent CI, 0.5 to 14), and 5.6 in those without thrombophilia (95 percent CI, 0.7 to 47; p-value for interaction, 0.6). These results were not reported separately according to mutation.

Wahlander et al. assessed the risk of VTE recurrence in relation to thrombophilic factors in probands receiving ximelagatran, an oral direct thrombin inhibitor (not presently available), or placebo.123 This study involved a group of participants recruited from the Thrombin Inhibitor in VTE (THRIVE III) trial.152 Among 111 FVL carriers in the treatment group, two had recurrences of VTE, as compared to 16 in the 125 with mutations assigned to placebo; this difference in recurrence rates was described as statistically significant (HR under 0.25; p-value not reported). The recurrence rate with treatment was very similar for individuals without FVL, suggesting that there was no interaction between FVL and the effect of ximelagatran in preventing recurrent VTE (p-value for the interaction, 0.92). Among 27 prothrombin G20210A carriers in the treatment group, none experienced a recurrence, while 2 of 27 carriers in the placebo group had a recurrence (HR not calculable). Recurrence rates with treatment were very similar for individuals without FVL or prothrombin G20210A, suggesting that there was no interaction between FVL or prothrombin G20210A and the effect of ximelagatran in preventing recurrent VTE (p-value for the interaction, 0.92 for FVL and 0.98 for prothrombin G20210A). There were no significant differences in the risk of bleeding in carriers of FVL or prothrombin G20210A when compared to non-carriers (p-value for the interaction, 0.60 for FVL and 0.16 for prothrombin G20210A).

Vossen et al studied the rate of recurrence of VTE in a cohort of patients belonging to thrombophilic families, classified according to whether they were receiving long-term anticoagulation or not.122 They focused on probands with a family history of VTE because of the potentially higher rates of recurrence among these individuals. All patients were recruited as part of the EPCOT trial. The mean follow-up was 5.6 years (range 1 to 7 years). Of 304 patients, 124 were on long-term anticoagulation, and 180 were not. The details of the anticoagulation regimens were not reported. The proportion of women was higher in the anticoagulation group (48 versus 35 percent). There were fewer FVL carriers in the long-term anticoagulation group than in the comparison group (13 and 44 percent, respectively). Of 79 patients with FVL who did not receive long-term anticoagulation, 13 had recurrences during 366 person-years (incidence rate, 3.5 percent per year; 95 percent CI, 1.9 to 6.1). Among the 13 FVL carriers who received anticoagulation, none had any recurrence during 43 person-years. This study showed that long-term anticoagulation decreased the rate of VTE recurrence among probands belonging to thrombophilic families. However a quantitative estimate was not calculable because there were no events in the group of patients receiving treatment. Confidence in the study’s results is low because this study was observational, and there were important differences in the baseline characteristics and duration of follow-up in the two groups. Also, there was a paucity of detail about the anticoagulation regimens.

### Effect of testing and results on other outcomes (KQ 4c)

Four studies addressed how probands’ and family members’ knowledge, behaviors, and healthcare experiences were affected by their being tested for FVL or prothrombin G20210A;153–157 only one study evaluated individuals with prothrombin G20210A153 (Table 11 and Appendix G, Evidence Table 21).

Two publications by Saukko et al. investigated the same population of patients but provided complementary information and are considered as one study here.155,156 Three studies were conducted in Europe154–157 and one in Canada.153 Two studies employed cross-sectional surveys of convenience samples of probands and family members to assess risk perception and behavioral effects following genetic testing.153,154 The other two studies used qualitative, structured interviews of probands and relatives to describe their experience during the process of testing as well as their interpretation of the results.155–157 In all studies, except that of Saukko et al,155,156 subjects were recruited from cohorts already enrolled in larger trials investigating venous thromboembolic outcomes in probands or relatives.

The quality of these studies was generally high (Appendix G, Evidence Table 20). Although all four studies used a cross-sectional design and looked at convenience samples of probands or relatives, the methods employed were appropriate to answer the research questions. The surveys used instruments that had been previously tested in patients with genetic mutations or that had been validated to measure specific constructs such as worry or risk perception.153,154 Both of the qualitative studies used appropriate data collection methods, including the exploration and exhaustion of predetermined themes, the use of trained interviewers, and the use of quotes to represent participants’ voices.155–157

Heshka et al surveyed the perception of VTE risk and changes in behavior following testing for FVL or prothrombin G20210A among first-degree relatives of probands.153 The survey response rate was 86 percent for relatives who carried the FVL mutation and 55 percent for non-carriers; otherwise, the 44 carriers and 26 non-carriers were similar in age, education, and income. More mutation carriers recognized trauma as a risk factor for VTE than did non-carriers, but otherwise there were no statistically significant differences between the two groups regarding their recognition of risk factors for VTE, despite the carriers having received counseling after testing. Behavior changes following testing were uncommon in both groups, but carriers were slightly more likely to have tried to avoid long trips since testing, to have stopped using oral contraceptive pills or hormone replacement therapy, to have discussed the results of the test with their surgeons or gynecologists, or to have been placed on anticoagulants during surgery or during or after childbirth. The results of this study suggest that testing for FVL and prothrombin G20210A and sharing the results with patients do not lead to a substantial change in risk perception or an important increase in preventive health behaviors.

Kaptein et al investigated whether the type of thrombophilic mutation and history of VTE affected the perception of risk and level of worry among probands or their relatives with FVL, when compared to other thrombophilic mutations.154 The core of the survey tool was a version of the Illness Perception Questionnaire adapted for patients with thrombophilia. Of the 251 individuals invited, 196 (78 percent) responded. Of these, 62 individuals had only FVL (no protein C, protein S, or antithrombin deficiency). This group included both relatives and probands, with and without a history of VTE. Overall, patients with a history of VTE had an increased perception of risk and worried more about VTE than did individuals without prior VTE. After controlling for age and prior VTE, patients with FVL had a significantly lower perception of risk of VTE than did individuals with antithrombin deficiency but a similar risk perception when compared to patients with protein C or S deficiency. Level of worry about thrombosis was similar across all thrombophilia groups. This study suggests that, among carriers of FVL, the level of worry is similar to that of carriers of other thrombophilic mutations, although individuals with antithrombin deficiency (which has the highest VTE risk of the four measured thrombophilias) had a higher perception of risk than did patients with the FVL mutation. However, worry and risk perception were not measured in non-carriers; therefore, although it appears that having the FVL mutation does not increase risk perception and worry beyond the levels seen with other relatively common thrombophilic mutations, this study did not specifically address how the testing process and knowledge of results affects individuals tested for FVL.

Bank et al conducted a qualitative study of asymptomatic relatives of probands with FVL to assess their overall experience with the testing process and how the results affected their daily lives.157 Of 26 relatives invited, 17 (65 percent) agreed to be interviewed. The topics covered during the open-ended interviews included stigmatization, perception of risk, and preventive behaviors. Among the participants, most found that the testing process itself was not stressful; all had received written information about the test prior to testing. Most exhibited knowledge of the most common risk factors for VTE (e.g., pregnancy, surgery), citing as the source of this knowledge the information provided during testing and the information obtained from providers after receiving the test results. Some participants related an increased level of worry about developing VTE, while some felt stigmatized by friends, family, or even their providers, who saw them as having a health condition. One person in the Netherlands who disclosed his test results to his employer was discriminated against in his disability insurance policy. Although the majority of participants indicated that testing had not altered their daily lives, many wanted to screen their children to decrease their risk of VTE from pregnancy or oral contraceptive use. This study suggests that although, overall, no drastic changes in mood or behavior were observed among individuals tested for FVL, testing generated concern about the individuals’ own health and the health of their children. The authors argued that the information provided on the day of testing and after the results were given played a crucial role in lessening patients’ concerns and improved their testing experience.

Saukko et al. assessed the level of understanding of the testing process and the implications of the results among probands and relatives referred for FVL testing by their primary care doctor or specialist.155,156 The study, which was carried out in the United Kingdom, involved structured qualitative interviews of 42 individuals (43 percent of the 97 invited to participate). The themes explored during the interviews included reasons for testing, how the results were relayed to the participants, how they reacted to the results, what they did with the information, and what they thought of the testing process as a whole. Twenty of the 42 participants had been referred because of a family history of VTE or thrombophilia; 10 had a prior history of VTE; and 5 were referred because of prior miscarriage. Seven participants were unaware they had been tested. Sixteen participants tested positive for FVL, although the results were for the most part not reported according to carriership status. Most participants did not consider thrombophilia testing to be different from the other tests ordered by their providers, even if they understood the increased risk of VTE.

The overall understanding of the FVL test and its implications fell along a spectrum: Most participants who understood the test well belonged predominantly to higher socio-economic strata, as compared to those with a poorer understanding of the test. Participants who received or obtained information about FVL prior to talking to their physicians (e.g., from relatives) were more likely to feel that the information given by their providers was sufficient or useful. Many did not receive written, detailed information about VTE risk factors or preventive behaviors from their providers when they were given their results. Participants also learned about the results of the tests in different ways, and this variability affected their behavior after receiving results. Those who were more informed about FVL sought information on their own, from relatives or the Internet, whereas the less-informed participants tended to assume that a lack of information from their providers meant that FVL was not an important condition. Most participants did not incorporate behaviors to reduce their risk for VTE into their daily routines as a result of the testing, although most participants who were aware of their positive status stated they had undergone testing to inform their decision to take hormonal therapy or to advise relatives on the matter.

These studies by Saukko et al. once again suggest that information given to patients at the time of testing affects their understanding of the process and the implications of the results.155,156 Furthermore, socio-economic factors such as income or literacy may potentially influence patients’ understanding of thrombophilia testing by limiting their access to supplementary information about the various tests. It is worth noting that although all patients were referred for FVL testing, many were actually referred for a thrombophilia panel, and so the attitudes or behaviors reported may not necessarily have been in response to FVL testing.

### Cost-effectiveness of FVL and Prothrombin G20210A Testing in the Case of Probands and Their Relatives (KQ 4d)

We identified six studies that assessed the cost-effectiveness of genetic testing and resultant changes in management158–163 and one study that assessed only effectiveness.164 Six of the studies employed decision-analytic modeling, with a single decision giving rise to a series of multiple possible outcomes, each of which was weighted according to the probability of its occurrence.158,160–164 Of these six studies, only one did not incorporate a Markov state-transition model, a technique that permits the consideration of iterative events over time.158 The seventh study used a prospective cohort to derive cost and outcomes data, with which the authors retrospectively modeled the costs and effectiveness of hypothetical changes in management.160 Four of the studies considered testing for FVL alone,160,161,163,164 while the remaining three evaluated testing for FVL along with prothrombin G20210A.158,159,162 Five of the studies modeled probands with a personal history of VTE,159,161–164 and the other two studies considered individuals with either a personal or family history of VTE.158,160

We first briefly describe the design, interventions, population, outcomes, results, conclusions, and quality deficits of each study (Table 12; Appendix G, Evidence Tables 25–27). In the tables, we present the results in 2007 U.S. dollars, although here in the text, we describe the results as reported in each paper.

The seven studies were of variable quality. They all had a clear statement of the objective and perspective, although the primary decision-maker for whom the study was conducted was specified only in the case of the United Kingdom National Health Service.158,160 A societal perspective was stated twice, without the incorporation of any indirect costs.159,161 The structure of the models was generally stated clearly and justified, together with the assumptions underlying the structure, the interventions examined, the time horizon, and the disease states included. When used, the health state quality weights were clearly stated and referenced, but no study critically discussed the health valuation methodology or options available. Only two of the five Markov models reported the cycle length.162,163 Data were well identified, modeled, and incorporated, although only three studies undertook a systematic review with a meta-analysis to define at least one model parameter.158,162,163 All studies assessed parameter uncertainty with sensitivity or scenario analysis, but none of the studies addressed structural uncertainty, and only one explicitly conducted subgroup analysis.158 Finally, internal consistency (the methodology of the model development) was not discussed in any study, although all but two compared their results to previous models’ results, providing a measure of external consistency.160,163

Sarasin and Bounameaux used a decision analysis with a Markov model and a 5-year time horizon to assess the effectiveness of extending anticoagulation from 3 months for FVL carriers and non-carriers following an initial lower-limb DVT to 1, 2, 3, 4, or 5 years in a hypothetical cohort.164 Quality weighting was explicitly not employed, since the authors expressed doubt that sufficient evidence existed to make the adjustments “reliable.” Instead, the results were provided in terms of the health outcomes: major bleeding events induced and recurrent DVT and pulmonary embolisms (PE) prevented. The best-case scenario, in which the point estimates most favorable for extended anticoagulation were modeled from the range of values identified in the literature (a high rate of PE, maximum anticoagulant efficacy, and low bleeding risk), revealed that the number of bleeding events induced outnumbered the number of pulmonary emboli prevented across all extended anticoagulant durations among carriers and non-carriers of FVL. However, the number of DVTs prevented among FVL carriers greatly exceeded the number of bleeding events induced across all extended anticoagulant durations, and the incremental ratio of DVT prevented to bleeding events induced was highest for 2 years of anticoagulation. Assuming that PE are of equal importance with bleeding events, the authors stated that the risk of bleeding must be below 2.5 percent/year in order for prolonged anticoagulation to be the more effective strategy. A major limitation of this analysis is that it did not take into consideration differences in how patients might view these different types of complications. The time horizon of this model may not have captured the full treatment effects, and the Markov cycle length was unspecified. The authors did not address methodological or structural uncertainty or internal or external consistency.

Marchetti et al used decision analysis with a Markov model and lifetime time horizon to assess the cost-effectiveness of testing for FVL with 2 years of warfarin anticoagulation for carriers following VTE in a hypothetical cohort of 60-year-old men.163 FVL testing with 2 years of anticoagulation for carriers was a cost-effective strategy (ICER = $12,833/QALY) when compared to no testing and 6 months of anticoagulation. However, this intervention was not cost-effective (ICER > $50,000/QALY) for individuals with a high risk of fatal bleeding on warfarin (>0.34 percent/year), low VTE recurrence rate (<9 percent in first 2 years), low anticoagulation efficacy (<74 percent), or low anticoagulation compliance (<94 percent). Cost figures were derived from the Italian health system. Quality deficits are discussed with the next study.

Building on their previous study, Marchetti et al. used the same model to assess the cost-effectiveness of testing for prothrombin G20210A and FVL, followed by 2 years of warfarin anticoagulation, in doubly heterozygous individuals.162 Testing for both mutations was cost-effective (ICER = $13,624/QALY) when compared to no testing and 6 months of anticoagulation, and if the testing costs were <$43, the testing strategy was cost-saving. Testing was not cost-effective (ICER > $50,000/QALY) for patient populations with a high bleeding risk (>1.6 percent in 6 months), low double-heterozygote prevalence (<1.4 percent), low pulmonary embolism mortality (<10 percent), or low anticoagulation efficacy (<65 percent). The quality deficits of this study apply to the previous study as well.163 The model structure examined a single anticoagulant duration, and the choice of this strategy was not discussed or justified. A half-cycle correction was not discussed, and structural uncertainty was not addressed. Internal consistency was not discussed.

Eckman et al. used decision analysis with a Markov model and a lifetime time horizon to assess the cost-effectiveness of testing for FVL and extending warfarin anticoagulation for 3 years or for life for carriers following a first VTE in a hypothetical cohort of 35-year-old women.161 The cost-effectiveness of extending the duration of anticoagulation was highly dependent on the rate of VTE recurrence used in the model. Testing followed by 3 years of anticoagulation was the dominant strategy (more effective and less costly) in scenarios that assumed a high rate of recurrence (16.3 percent/year) for the first 3 years and no or low (2.3 percent/year) recurrence beyond. If the rate of recurrence remained constant (7.3 percent/year), lifelong anticoagulation was the most cost-effective strategy (ICER = $16,823/QALY) when compared to no testing with 6 months of anticoagulation. Lifelong anticoagulation would be less cost-effective in patient populations with a low FVL prevalence, low risk of recurrent VTE, or risk factors for bleeding on anticoagulant therapy. Structurally, the authors claimed a societal perspective, although only direct healthcare costs were modeled, and the cycle length of the Markov model was not explicitly stated. A half-cycle correction was not mentioned, the quality of life weights were not justified, and only the costs were discounted. Structural uncertainty and internal consistency were not addressed.

Auerbach et al. used decision analysis with a Markov model and lifetime time horizon to assess the cost-effectiveness of a hypercoagulability testing panel and warfarin anticoagulation for 6, 12, 18, 24, or 36 months, or for life, following an apparently idiopathic deep vein thrombosis in a hypothetical cohort of 40-year-old individuals.159 In the base case analysis, extending warfarin anticoagulation for 24 months following a positive test result was the most cost-effective option (ICER $11,100/QALY) when compared to the least costly option of not testing and treating for 24 months. Each test was evaluated separately in the hypercoagulability panel, and the authors concluded that tests detecting disorders present in at least 5 percent of the population that confer a relative risk exceeding 1.25, including FVL and prothrombin G20210A, should be included. The authors claimed a societal perspective but incorporated only direct costs, and the cycle length of the Markov model was unspecified. A half-cycle correction was not mentioned, the utility weights were not justified, and structural uncertainty was not addressed. Internal consistency was not discussed, although the results were discussed in relation to similar studies for individual hypercoagulable disorders.

Clark et al .used the cost and outcomes data from a prospective cohort of 967 pregnant women in the United Kingdom to assess the cost-effectiveness of FVL testing and enoxaparin anticoagulant prophylaxis in preventing pregnancy-related vascular complications over the 8-month time horizon from 12 weeks gestation to 6 weeks postpartum.160 All women were screened for FVL, but the results of the test were not disclosed to the women until the conclusion of the study. No women actually received anticoagulant prophylaxis, but the hypothetical impact of treating FVL carriers with an assumed efficacy of 50 percent was modeled ex post facto. While testing all women and treating the FVL carriers identified was the most effective approach, testing only those women with a personal or family history of VTE was a more cost-effective approach (ICER = £7,535/vascular complication prevented) when compared to no screening or prophylaxis. The structure of the model was not described, and the scope, outcomes, and time horizon were not justified. Data were largely derived from the cohort, but the assumption of prophylactic efficacy was stated without discussion or justification. There was no discussion of treatment alternatives, and quality of life weighting was not used or discussed. There was also no assessment of internal or external consistency or uncertainty beyond the parameter of anticoagulant efficacy.

Wu et al. used a decision analysis model with a 12-month time horizon to assess the cost-effectiveness of universal or selective screening for FVL and the resultant changes in management for carriers in four cohorts with high VTE risk: women prior to combined oral contraceptive prescription, women prior to hormone replacement therapy, pregnant women at 6 weeks of gestation, and patients prior to major orthopedic surgery.158 FVL carriers in the first two cohorts did not receive hormonal therapy, and carriers in the second two cohorts received 3 months of thromboprophylaxis in an effort to prevent adverse events (VTE or pregnancy-related vascular complications). Selective screening was based on a personal or family history of VTE. While universal screening was more effective in all cohorts, selective screening was more cost-effective in all cohorts. Selective screening was most cost-effective when compared to no screening in the case of the hormonal therapy cohort (ICER = £2,447/VTE prevented), followed by the surgery cohort (£9,136/VTE prevented), and it was less cost-effective in the case of the oral contraceptive cohort (£79,085/VTE prevented) and the pregnancy cohort (£81,250/pregnancy-related vascular complication prevented). The short time horizon of the model may not have captured the full treatment effects, and the absence of quality weights made comparing the health outcomes difficult. Structural uncertainty was not addressed, and internal consistency was not discussed.

### Summary of the evidence for Key Question 4

We summarize the evidence regarding the clinical utility of testing for FVL and prothrombin G20210A as follows:

- Low-grade evidence indirectly supported the hypothesis that patient management by physicians may change on the basis of the results of testing for FVL or prothrombin G20210A.
- There was no direct evidence that testing for these mutations, and the resultant management, can reduce VTE related-outcomes in individuals who have had VTE or in the probands’ family members who have been tested.
- There was moderate-grade evidence that treatment can reduce recurrent events in patients with FVL or prothrombin G20210A; however, the magnitude of this relative reduction was comparable to that seen in individuals without mutations.
- There was moderate-grade evidence that neither harms nor benefits have been conclusively demonstrated in individuals with VTE or their family members when tested for FVL or prothrombin G20210A.
- There was only low-grade evidence, coming from models, to suggest that testing for FVL alone, prothrombin G20210A alone, or the two tests in combination is cost-effective when caring for selected patients with VTE (those with a high risk of recurrence and/or low risk of bleeding) or their family members.