# Methods

The Evaluation of Genomic Applications in Practice and Prevention (EGAPP) initiative was established by the Office of Public Health Genomics at the Centers for Disease Control and Prevention (CDC) to address the increasingly urgent need for timely and objective information that would allow health care providers and payers, policymakers, and consumers to identify genetic tests that are safe and useful. The CDC expects the EGAPP initiative to provide guidance on the appropriate use of genetic tests in practice, based on available evidence. The independent, multidisciplinary EGAPP Working Group, established in April, 2005, requested this review on the topic of testing for Factor V Leiden (FVL) and prothrombin G20210A.

## Establishing a Technical Expert Panel

We began by recruiting experts to form a Technical Expert Panel. These experts were asked to provide input that would help us to refine the key questions to be answered with this review, to examine our list of articles identified for inclusion, and to suggest additional sources to search for evidence. These experts were also invited to be the peer reviewers of our finished report. The panel included four faculty members from the Johns Hopkins University. One of the four Hopkins panelistswas a bioethicist and the former Assi stant Director of the National Human Genome Research Institute, one was a clinical investigator with extensive experience with genetic testing for colon cancer, one was the director of our special coagulation laboratory, and one was the director of our anticoagulation management service and an expert on hypercoagulable states. Our external panelists included experts in thrombophilia and the management of venous thromboembolism (VTE); a genetic counselor; three members of the EGAPP Working Group with expertise in medical screening, genetics, and methodologies of genetic testing; a family physician; and a patient affected by these mutations who is a leader in the National Alliance for Thrombosis and Thrombophilia (see Appendix A).

## Analytic Framework

We used an analytic framework to identify the evidence required to answer our Key Questions. The analytic framework (see Figure 1) was developed with the involvement of our Task Order Officer from the Agency for Healthcare Research and Quality (AHRQ) and the Technical Expert Panel.

Figure 1 FVL and prothrombin testing for the prevention of venous thromboembolic events: Analytic framework

* harms include management-related outcomes and emotional/behavioral/social sequelae of testing

** benefits include VTE-related outcomes, management-related outcomes, emotional/behavioral/social sequelae of testing

† intervention (or change in management or recommendations) may or may not vary with test result Q = Question; VTE = venous thromboembolism

## Key Questions

Guided by the analytic framework, we developed the following key questions (KQs). Our population was defined as adults with a personal history of VTE, or adult family members of individuals identified as having an FVL and/or prothrombin G20210A mutation(s).

- KQ1 [Overarching question] Does FVL testing, alone or in combination with prothrombin G20210A testing, lead to improved clinical outcome (e.g., avoidance of a recurrent VTE) in adults with a personal history of VTE or to improved clinical outcome (e.g., avoidance of an initial VTE) in adult family members of mutation-positive individuals? Are the testing results useful in medical, personal, or public health decisionmaking?
- KQ2 What is the evidence regarding the analytic validity of existing diagnostic tests for the FVL mutation and the prothrombin G20210A mutation, specifically their analytic sensitivity and specificity, reproducibility, and robustness (sources of variability)?
- KQ3a What is the evidence that the presence of FVL alone, prothrombin G20210A alone, or the two in combination predicts the risk of recurrent VTE in individuals (probands) who have had VTE and predicts the risk of VTE in the probands’ family members who have been tested? Does the testing add predictive information beyond clinical data?
- KQ3b What is the evidence that demographic or clinical factors modify the relationship between the presence of FVL or prothrombin G20210A and the risk of VTE?
- KQ4a What is the evidence that clinicians manage patients differently based on the results of testing for FVL or prothrombin G20210A? How do clinicians manage anticoagulation in individuals who have had testing, as compared to those who have not had testing? What other diagnostic tests do clinicians order or not order, based on testing results? What recommendations do clinicians make regarding other therapies and exposures, based on testing results?
- KQ4b What is the evidence that testing, and the resultant management, reduces VTE related-outcomes or has other benefits in individuals who have had VTE or in the probands’ family members who have been tested?
- KQ4c What is the evidence of harms to individuals with VTE or to the probands’ family members who are tested for FVL or prothrombin G20210A as a result of testing or as a result of changed management based on the test results?
- KQ4d What is the evidence that testing for FVL alone, prothrombin G20210A alone, or the two tests in combination is a cost-effective strategy when caring for a patient with VTE or a family member of a proband?

## Search Strategy

Searching the literature involved identifying reference sources, formulating a search strategy for each source, and executing and documenting each search. We also searched for medical subject heading (MeSH) terms that were relevant to the genetics of Factor V and prothrombin. We used a systematic approach for searching the literature, with specific eligibility criteria, to minimize the risk of bias in selecting articles for inclusion in the review. The systematic approach was intended to help identify gaps in the published literature.

Our comprehensive search included electronic and hand searching. We searched five databases, MEDLINE^®^ (1950 through December 2008), EMBASE^®^ (1974 through December 2008), The Cochrane Library (Issue 2, 2008), the Cumulative Index to Nursing & Allied Health Literature (CINAHL^®^; 1982 through December 2008) and PsycInfo^©^, to identify primary literature on the analytic validity, clinical validity, and clinical utility of testing for FVL and prothrombin G20210A. Hand searching for possibly relevant citations took two forms. First, from our electronic search, we identified the 11 journals (see Appendix B) that were most likely to publish articles on this topic (i.e., these journals had the highest number of abstracts and articles included in the review). We scanned the table of contents of each issue of these journals for relevant articles from March 2008 through September 2008. For the second form of hand searching, reviewers reviewed eligible articles and flagged references of interest for the team to compare to the existing database.

Search strategies specific to each database were designed to enable the team to focus the available resources on articles that were the most likely to be relevant to the key questions. We initially developed a core strategy for MEDLINE^®^, accessed via PubMed^®^, based on an analysis of the MeSH terms and text words of key articles identified a priori. The PubMed^®^ strategy formed the basis for the strategies developed for the other electronic databases (see Appendix C). The results of the searches were downloaded and imported into ProCite^®^ version 5 (the Thompson Corporation, Stamford, CT). We used the duplication scan feature in ProCite^®^ to delete citations already retrieved. From ProCite^®^, the articles were uploaded to SRS 4.0 (TrialStat! Corporation, Ottawa, Ontario, Canada), a Web-based software package developed for systematic review data management. This database was also used to store citations in portable document format (PDF) and to track the search results at the title review, abstract review, article inclusion/exclusion, and data abstraction levels. A list of excluded articles is presented in Appendix D.

## Study Selection

There were a total of six reviewers who were paired, so that each pair included an expert in the content of this review. Two reviewers independently conducted title scans in a parallel fashion. For a title to be eliminated at this level, both reviewers had to indicate that it was ineligible. If the two reviewers did not agree on the eligibility of an article, it was promoted to the next level (see Appendix F, Title Review Form). The title review phase was designed to capture as many studies as possible that reported on the analytic validity, clinical validity, and clinical utility of testing for FVL and prothrombin G20210A. All titles that were identified as potentially addressing these issues were promoted to the abstract review phase.

Abstracts were reviewed independently by two investigators. Abstracts were excluded if both investigators agreed that the article met one or more of the following exclusion criteria: It (1) was not relevant to any of the key questions; (2) did not include any human data; (3) contained no original data; (4) was not conducted among adults; or (5) was not published in English. Differences of opinion regarding abstract eligibility were resolved through consensus adjudication. At this level of review, the reviewers were also asked to identify to which Key Question(s) the article might apply if it was eligible for review.

Because of the broad array of potentially eligible articles obtained at the abstract review phase, full articles selected for review underwent another independent parallel review by two investigators to determine whether the articles should be included in the full data abstraction. In addition to the exclusion criteria used for the abstract review, there were additional exclusion criteria for each Key Question (see Table 1).

Table 1 List of additional exclusion criteria by Key Question

Question | Criteria | Explanation
KQ2 | - Published prior to 2000; - Evaluated only APC resistance; - Evaluated only DNA extraction methods; - Did not report concordance, discordance, or reproducibility; - Evaluated fewer than 10 samples
KQ3 | - Did not report results separately for FVL and/or prothrombin G20210A; - Studied fewer than 10 probands or fewer than 10 family members; - Did not objectively confirm VTE event; - Was a case-control or retrospective cohort study of probands; - Patients described in another publication | We opted to exclude retrospective studies of probands, since this study design is more subject to biases than is a prospective design. We opted to include retrospective studies of family members because we expected to have few, if any, prospective studies.
KQ4 | - Did not study probands or family members; - Fewer than 80% of the probands had the FVL or prothrombin G20210A mutations; - Fewer than 80% of the probands had VTE | We required that 80% of the study population had the mutations of interest if it was a study including family members with other hypercoaguable conditions and results were not reported separately by mutation. We required that 80% of the probands had VTE if it was a study of individuals with mutations, in keeping with our stated population of interest.

APC = activated protein C; DNA = deoxyribonucleic acid; FVL = Factor V Leiden; KQ = Key Question; VTE = venous thromboembolism

At this phase of the review, the investigators determined which of the Key Questions each article addressed (see Appendix E, Article Inclusion/Exclusion Form). If the articles were deemed to have applicable information, they were included in the full data abstraction. Differences of opinion regarding article eligibility were resolved through consensus adjudication.

## Data Abstraction

We used a systematic approach to extracting data in order to minimize the risk of bias in this process. By creating standardized forms for data extraction, we sought to maximize consistency in identifying all pertinent data available for synthesis.

Each article underwent double review by study investigators for full data abstraction and assessment of study quality. For all data abstracted from studies, we used a sequential review process. In this process, the primary reviewer completed all data abstraction forms. The second reviewer checked the first reviewer’s data abstraction forms for completeness and accuracy. Reviewer pairs were formed to include personnel with both clinical and methodological expertise. Reviewers were not masked to the articles’ authors, institutions, or journal.30 In most instances, data were directly abstracted from the article text. If possible, relevant data were also abstracted from figures. Differences of opinion were resolved through consensus adjudication. For assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms (see Appendix F, Data Abstraction Review Forms). For articles that applied to Key Question 2, we abstracted information on the sample selection criteria, the test operators, the characteristics of the DNA extraction process, the experimental test, the reference standard, the commercial instruments used, the concordance rates, and the explanation of any false positives or false negatives, if applicable. For articles that applied to Key Question 3, we abstracted information on study characteristics (i.e., study design, enrollment dates, location, inclusion criteria, genetic test used, duration of follow-up, and radiographic and clinical surveillance), population characteristics (i.e., age, gender, idiopathic VTE, oral contraceptive or hormone use, pregnancy, other precipitating factors, and other thrombotic mutations), and the results. For articles that applied to Key Question 4, we abstracted information on the study characteristics (i.e., study design and location), population characteristics (i.e., patients or providers, age, race, gender, genotype, socioeconomic status, and specialty of the providers), the main objective of the study, and the results.

All information from the article review process was entered into the SRS 4.0 database by the individual completing the review. Reviewers entered comments into the system whenever applicable. The SRS 4.0 database was used to maintain and clean the data, as well as to create detailed evidence tables and summary tables (see Appendix G and Summary Tables).

## Study Quality Assessment

The study aspects considered in our quality assessment varied according to the question being addressed and according to the study design. As part of our dual, independent review of study quality, we judged articles on several aspects of each study type’s internal validity. Quality assessment of diagnostic studies for Key Question 2 was designed by selecting elements from the Standards of Reporting of Diagnostic Accuracy (STARD) Initiative31 and included: (1) adequate descriptions of the setting, the experimental test, and the reference standard; (2) a statement about testing being conducted without knowledge of the reference standard results; (3) a statement about all specimens being tested with both the experimental test and reference standard; (4) the reporting of a summary index and a measure of variability; and (5) a description of the funding source. Quality assessment for Key Question 3 was based on quality forms previously developed by our Evidence-based Practice Center (EPC).32, 33 This assessment included items about the setting, inclusion/exclusion criteria, key characteristics of the enrolled subjects, losses to follow-up, and the funding source. Quality assessment of the qualitative studies for Key Question 4 included items from The Joanna Briggs Institute Qualitative Assessment and Review Instrument,34 supplemented with quality items previously developed by our EPC. The qualitative study quality assessment form included: (1) a statement locating the researcher culturally or theoretically, (2) a statement of ethical approval, (3) a description of the theoretical basis for the study, (4) a description of why patients were selected, (5) adequate representation of the participants and their voices, (6) composition of the interview setting to maximize data gathering, (7) reporting of theme exhaustion, (8) a clear description of the data collection process, (9) addressing the influence of researchers on research and vice versa, (10) the use of triangulation, and (11) the development of a concept, model, or theory based on the data collected. Quality assessment of surveys for Key Question 4 was based on quality forms previously developed by our EPC and included: (1) a description of the theoretical basis for the study; (2) a statement of ethical approval; (3) a description of the setting, inclusion/exclusion criteria, and key characteristics of the study participants; (4) survey completion rates; and (5) a discussion of the validity, reliability, and interpretability of the survey instrument. Quality assessment of cost-effectiveness analyses for Key Question 4 was based on a review of guidelines for good practice in decision-analytic modeling in health technology assessment35 and included items regarding the structure, data, and consistency.

A senior reviewer adjudicated any discrepancies in the quality assessment.

## Applicability

Throughout the report, we describe the applicability of studies in terms of the extent to which the study population and testing procedure were relevant to the process of testing patients and their family members in the United States. We evaluated the applicabil ity of studies in terms of: (1) the study population, (2) the genetic tests used to determine mutation status, (3) the eligibility criteria, (4) the outcome rates and measures, (5) the treatment regimen, (6) the interventions, (7) the follow-up time, and (8) the standards of care.

## Data Synthesis

For each Key Question, we created a set of detailed evidence tables containing all the information extracted from the eligible studies. The investigators reviewed the tables and eliminated items that were rarely reported.

In calculating the concordance rates for the studies that examined the analytic validity of the tests for detecting the mutations, we used the initial test results before any resolution by repeat testing. In the tables presenting these results (in Chapter 3), if the concordance was less than 100 percent, we provide details about the discordant results.

We conducted meta-analyses of the studies addressing the clinical validity of the tests, when there were sufficient data (three or more studies) and the studies were qualitatively homogeneous with respect to key variables (population characteristics, study duration, mutation status, and length of follow-up). When it was inappropriate to combine studies quantitatively, we qualitatively summarized the results.

For the pooling, we used the number of events and count of the patients under observation in each group. We calculated a pooled estimate of the odds ratio for VTE in probands and separately in family members. We used a random effects model with the DerSimonian and Laird method for calculating between-study variance.36 The random effects model was chosen because we anticipated some heterogeneity among the studies. We repeated the pooling using Mantel-Haenszel (M-H) fixed effect methods and Peto fixed effects methods. As the outcome events were not always rare, the Peto methods yielded markedly different pooled estimates for some of the comparisons. The M-H fixed effects and random effects pooled estimates were quite similar.

We assessed heterogeneity among the studies considered using a standard chi-squared test and a significance level of alpha ≤0.10. We also examined heterogeneity among studies with an I2 statistic, which describes the variability in effect estimates that is due to heterogeneity rather than random chance.37 A value greater than 50 percent may be considered to indicate substantial variability.

We tested for publication bias in two ways. First, we used the Duval and Tweedie nonparametric “trim and fill” method of accounting for publication bias in meta-analysis.38 This methodology explores whether the inclusion of “missing” studies would alter the pooled odds ratio. We also used the Egger’s test to evaluate the likelihood of missing studies.39 Finally, we sequentially removed each study from the calculation of the pooled estimates and recalculated the pooled odds ratios. In this way, we were able to assess the impact on the odds ratios of one particularly influential study.

All statistical analyses were conducted using STATA (Intercooled, version 9.0, StataCorp, College Station, TX).

## Data Entry and Quality Control

Initial data were abstracted by the investigators and entered directly into Web-based data collection forms using SRS^®^ 4.0 (TrialStat! Corporation, Ottawa, Ontario, Canada). After a second reviewer reviewed the data, the adjudicated data were re-entered into the Web-based data collection forms by the second reviewer. Second reviewers were generally more experienced members of the research team, and one of their main priorities was to check the quality and consistency of the first reviewers’ answers. If problems were recognized in a reviewer’s data abstraction, the problems were discussed at a meeting with the reviewers.

## Rating the Body of Evidence

At the completion of our review, we graded the quantity, quality, and consistency of the best available evidence addressing the Key Questions by adapting an evidence-grading scheme recommended by the Grading of Recommendations Assessment, Development and Evaluation (GRADE) Working Group.40 We assessed the strength of the study designs for each question. To assess the quantity of evidence, we focused on the number of studies with the strongest design. We also assessed the quality and consistency of the best available evidence, including assessment of the limitations affecting individual study quality (using the individual study quality assessments), certainty regarding the directness of the observed effects in the studies, the precision and strength of the findings, and the availability (or lack) of data to answer the Key Question. We classified evidence bodies pertaining to the Key Questions into the following categories: (1) “high” grade, indicating confidence that further research is very unlikely to change our confidence in the estimated effect in the abstracted literature; (2) “moderate” grade, indicating that further research is likely to have an important impact on our confidence in the estimates of effects and may change the estimates in the abstracted literature; (3) “low” grade, indicating the further research is very likely to have an important impact on confidence in the estimates of effects and is likely to change the estimates in the abstracted literature. We also noted when there was no available evidence. This framework for grading the body of evidence is consistent with that suggested by the EGAPP working group.41