# Introduction

## Venous Thromboembolism

Venous thromboembolism (VTE) refers to pathologic thrombosis in the venous circulation. Although the most frequent venous thromboembolic event is deep venous thrombosis (DVT) in the veins of the legs, thromboses can also occur in the veins of the upper extremities, pelvis, abdomen, and cerebral venous sinuses. Pulmonary embolism is the main life-threatening complication of DVT, in which a portion of the venous thrombus is carried to the pulmonary arteries by blood flow, potentially obstructing the pulmonary vasculature. VTE and its complications are a common cause of morbidity and mortality in the United States. Data from the Rochester Epidemiology Project indicate that the average annual incidence of isolated DVT is 48 per 100,000 individuals, and that of pulmonary embolism (with or without DVT) is 69 per 100,000.^1^ Others estimate the incidence rate to be similar, at approximately 100 per 100,000, with approximately one-third manifesting as pulmonary embolism and two-thirds as DVT alone.2

Incident VTE is triggered by a confluence of modifiable and unmodifiable risk factors. Some of these risks are situational. Trauma or surgery may lead to direct endothelial injury, exposing circulating clotting factors to the thrombogenic material of the vessel wall (such as tissue factor). Stasis of blood is a precipitant of thrombosis, particularly when blood pools in the deep veins of the legs. Acquired alterations in coagulability are also precipitated by systemic illnesses, particularly malignancies, infection, nephrotic syndrome, and the antiphospholipid syndrome. These conditions are associated with varying degrees of inflammation, which activates hemostasis and/or changes in blood constituents (such as a loss of anti-clotting proteins in nephrotic syndrome, or the activation of the thrombotic cascade by tumor products). Primary hematological disorders, including myeloproliferative disorders such as polycythemia vera and essential thrombocythemia, increase the risk of thrombosis,3 as do sickle cell anemia, thalassemia, and paroxysmal nocturnal hemoglobinuria.4 Heparin-induced thrombocytopenia is a unique condition associated with venous or arterial thrombosis in up to 50 percent of patients in whom it develops.5 Hyperhomocysteinemia is associated with increased risk of both venous and arterial thrombosis and can result from inherited enzymopathies or from acquired disorders of homocysteine metabolism, including renal failure and folate and vitamin B12 deficiency.6–8 Hormonal therapies, primarily estrogens, are prothrombotic, as is pregnancy and the post-partum state.3 Advanced age, too, is a potent risk factor for VTE.9 Genetic risk factors for venous thrombosis include: deficiencies of endogenous anticoagulant proteins, antithrombin III, protein C, or protein S; and elevated levels of clotting factors VIII, IX, and XI; and possibly the 5,10-methylenetetrahydrofolate reductase C677T polymorphism.3 Although one would expect that disturbances of normal fibrinolytic function (e.g., excessive levels of plasminogen activator inhibitor-1 or α_2_-antiplasmin, or deficiencies in Factor XII or tissue plasminogen activator) would contribute to a hypercoaguable state, clinical evidence for such effects is lacking.10–12 Rarely, dysfibrinogenemia is associated with an increased tendency toward clot formation.13

This report focuses on two specific genetic factors associated with an increased risk of VTE, the Factor V Leiden (FVL) mutation and the prothrombin G20210A mutation. These mutations will be described in detail below.

The risk factors for recurrent venous thrombosis differ from the risks for incident events; men are more likely to have recurrent events than are women.14 In patients who stop taking anticoagulant medications following treatment for an acute event, recurrent DVT occurs in about 20 percent of patients within 5 years of the first event and in 30 percent within 10 years.15, 16 However, continued anticoagulation treatment is highly effective in suppressing recurrent disease.17

## Diagnosis and Treatment

Many diagnostic tests and testing strategies have been evaluated with the goal of maximizing both the sensitivity and specificity of the diagnosis, so that an expeditious diagnosis can be made and treatment promptly initiated. Treatment of the incident event happens in two phases: Treatment begins with short-term use of a parenteral anticoagulant (and sometimes thrombolytic therapy) and then usually continues with a vitamin K antagonist, most commonly warfarin. In some instances, parenteral therapy is continued instead of warfarin.18 The duration of therapy depends on whether the patient is considered to have continuing risk factors for recurrence. Much effort has been devoted recently to quantifying the risk of recurrent thrombosis, with methods aimed at detecting whether a thrombophilic state persists. This effort has included measurement of D-dimer production19 and assessment of persistence of thrombosis by ultrasonography,20 as well as assessment of ongoing clinical risk factors. If the patient has a persistent risk factor for thrombosis, anticoagulant therapy is often continued, sometimes for the lifetime of the patient. The clinician and patient also try to reduce exposure to any modifiable prothrombotic risks as a secondary means of preventing additional events, and they may use mechanical or pharmacological means of preventing thrombosis at high-risk times, such as during hospitalization or pregnancy.

The question of whether a patient has ongoing risk is directly associated with the subject of this report, an evaluation of the value of testing for FVL and prothrombin G20210A. A diagnostic test has value only if the process of testing or the results of testing lead to a change in outcome. In the case of venous thrombosis, a test that predicts recurrent events is appropriate if there is an intervention that can modify the risk of events. In this case, use of anticoagulants can modify the risk. Also, removal or avoidance of prothrombotic contributors (such as hormonal therapy) modifies the risk. It is then easily argued that identification of genetic risks may be important if it permits actions can be taken that alter outcomes. Even if the risk factor itself is not modifiable, management of the patient based on knowledge of the risk factor can change outcomes.

## Genetic Mutations Associated with VTE: FVL and Prothrombin G20210A

FVL refers to a base change (from G to A at position 1691) in the gene coding for the Factor V protein, an amino acid substitution that eliminates one of three activated protein C cleavage sites in Factor V. As a result, Factor V is inactivated to a lesser extent and persists for a longer period in the circulation, leading to more thrombin generation.21 In the United States, a single FVL allele is present in about 5, 2.2, and 1.2 percent of the Caucasian, Hispanic, and African American populations, respectively; overall, about 1 in 5,000 individuals is homozygous for the mutation.22, 23 The FVL mutation has been estimated to be present in 15 to 20 percent of patients with first venous thrombosis21 and is the most common heritable prothrombotic riskfactor in the United States. In population-based studies, FVL increases the risk of a first venous thrombosis 4- to 7-fold in heterozygous individuals and 40- to 80-fold in homozygous individuals.21, 22

The prothrombin (Factor II) mutation is the second most common inherited risk factor for thrombosis. In the United States, the prevalence of this allele is 1.1 percent in Caucasians and Hispanics and 0.3 percent in African Americans.24 The mutation in the gene, G20210A, is associated with an elevation of prothrombin levels to about 30 percent above normal in heterozygotes and to 70 percent above normal in homozygotes. This mutation is present in about 2 percent of the population and in 6 percent or more of patients who present with a first VTE. Six to 12 percent of individuals who are heterozygous for FVL and have VTE also have the prothrombin G20210A mutation (double heterozygotes).21, 22, 25 Heterozygotes are at a two- to four-fold increased risk of an initial thrombosis.22, 26 Individuals who are doubly heterozygous for FVL and prothrombin G20210A (about 1 in 1,000 Americans) have an estimated 20-fold increased risk when compared to individuals without either mutation, suggesting a multiplicative elevation in risk.21, 22, 25

## Methods for Identifying Mutations

Testing for these mutations is widely offered in the United States. In December 2003, the U.S. Food and Drug Administration (FDA) approved the first DNA-based laboratory tests specifically designed for FVL and prothrombin G20210A detection, manufactured by Roche Diagnostics Corporation (LightCycler Instrument). In 2007, Autogenomics Inc. received approval for their INFINITI System Assay for detection of the mutations. These tests are FDA-approved for use as an “aid to diagnosis in the evaluation of patients with suspected thrombophilia.”27, 28 These commercially available tests have demonstrated, in their pre-approval testing, sufficient analytic validity to receive approval for use. They were not required to demonstrate clinical validity or clinical utility (to be defined below). Laboratories have also developed numerous other methods for detecting these mutations and do not use the commercially available systems; the analytic validity of these tests, however, is not well known.

## Objectives of this Evidence Report

Our goal was to review the evidence regarding the value of testing for these mutations in two specific populations: (1) individuals who have had a VTE event (probands), and (2) the family members of probands with mutations. We did not aim to review the evidence regarding testing for these mutations as a screening strategy (for example, in a population with no known risks for disease, or in other clinical settings such as before use of oral contraceptives or hormonal therapy). Similarly, it was not our intention to review the use of these genetic tests in other clinical settings, such as in the investigation of fetal loss.

To achieve our goal, we developed an analytic framework (described in Chapter 2). To understand this framework, one must be familiar with the definitions of analytic validity, clinical validity, and clinical utility.29 Analytic validity is a measure of an assay’s performance, which includes its analytic sensitivity and specificity as well as its robustness. Robustness refers to how resistant the test is to changes in pre-analytic and analytic variables, such as the source of the specimen or the temperature of the environment. Included in the framework of analytic validity is the assessment of laboratories’ quality control activities. These are procedures that ensure that the results fall within specified limits.

Clinical validity is the extent to which the presence of the mutation predicts the clinical condition of interest. Clinical validity, therefore, includes the sensitivity and specificity of the test, as well as the predictive values of positive and negative tests, taking into account the disorder prevalence. Clinical validity may also be affected by penetrance, which is the relationship between the genotype and phenotype. In this report, the clinical condition of interest is recurrent venous thrombosis in the probands (because they have all had an incident event) and a first thrombotic event in the family members. Therefore, our assessment of clinical validity involves identifying the extent to which the presence of the mutations predicts venous thrombosis.

Clinical utility refers to the impact of testing on outcomes. This evaluation involves knowing the availability and effectiveness of interventions employed in response to the test results, and an understanding of the risks and benefits when the test is used in routine practice.

The report is structured as follows: In Chapter 2, we present our methods, which include a description of the Key Questions addressed in this evidence report, the analytic framework we constructed, and the methods used in our literature search, data abstraction, and synthesis of results. In Chapter 3, we present our results and assessment of the strength of the evidence for each Key Question, in terms of the analytic validity, clinical validity, and clinical utility of testing. Chapter 4 is our discussion and includes a review of the grading of the strength of the evidence and the implications of our findings for future research.