# Evidence Tables

Evidence Table 1 Quality of studies addressing Analytic Validity of Tests to Identify Factor V Leiden and Prothrombin G20210A Mutations

TABLE NOT AVAILABLE

Reference List
1. Hessner MJ, Budish MA, Friedman KD. Genotyping of factor V G1691A (Leiden) without the use of PCR by invasive cleavage of oligonucleotide probes. Clin Chem 2000; 46(8 Pt 1):1051–6.; 2. Kowalski A, Radu D, Gold B. Colorimetric microwell plate detection of the factor V Leiden mutation. Clin Chem 2000; 46(8 Pt 1):1195–8.; 3. Ledford M, Friedman KD, Hessner MJ, Moehlenkamp C, Williams TM, Larson RS. A multi-site study for detection of the factor V (Leiden) mutation from genomic DNA using a homogeneous invader microtiter plate fluorescence resonance energy transfer (FRET) assay. J Mol Diagn 2000; 2(2):97–104.; 4. Nauck M, Marz W, Wieland H. Evaluation of the Roche diagnostics LightCycler-Factor V Leiden Mutation Detection Kit and the LightCycler-Prothrombin Mutation Detection Kit. Clin Biochem 2000; 33(3):213–6.; 5. Pecheniuk NM, Marsh NA, Walsh TP. Multiple analysis of three common genetic alterations associated with thrombophilia. Blood Coagul Fibrinolysis 2000; 11(2):183–9.; 6. Sanders Sevall J. Factor V Leiden genotyping using real-time fluorescent polymerase chain reaction. Mol Cell Probes 2000; 14(4):249–53.; 7. Benson JM, Ellingsen D, El-Jamil M et al. Factor V Leiden and factor V R2 allele: high-throughput analysis and association with venous thromboembolism. Thromb Haemost 2001; 86(5):1188–92.; 8. Crockett AO, Wittwer CT. Fluorescein-labeled oligonucleotides for real-time pcr: using the inherent quenching of deoxyguanosine nucleotides. Anal Biochem 2001; 290(1):89–97.; 9. Humeny A, Bonk T, Berkholz A, Wildt L, Becker CM. Genotyping of thrombotic risk factors by MALDI-TOF mass spectrometry. Clin Biochem 2001; 34(7):531–6.; 10. Parks SB, Popovich BW, Press RD. Real-time polymerase chain reaction with fluorescent hybridization probes for the detection of prevalent mutations causing common thrombophilic and iron overload phenotypes. Am J Clin Pathol 2001; 115(3):439–47.; 11. Potter CG, Liu YT, Rees DC. Factor V Leiden mutation screened by PCR and detected with lanthanide-labeled probes. Genet Test 2001; 5(4):291–7.; 12. Reyes AA, Ugozzoli LA, Lowery JD et al. Linked linear amplification: a new method for the amplification of DNA. Clin Chem 2001; 47(1):31–40.; 13. Rhodes RB, Lewis K, Shultz J et al. Analysis of the factor V Leiden mutation using the READIT Assay. Mol Diagn 2001; 6(1):55–61.; 14. Tsongalis GJ, Rainey BJ, Hodges KA. READIT: a novel technology used in the interrogation of nucleic acid sequences for single-nucleotide polymorphisms. Exp Mol Pathol 2001; 71(3):222–5.; 15. Evans JG, Lee-Tataseo C. Determination of the factor V Leiden single-nucleotide polymorphism in a commercial clinical laboratory by use of NanoChip microelectronic array technology. Clin Chem 2002; 48(9):1406–11.; 16. Huang TJ, Liu M, Knight LD, Grody WW, Miller JF, Ho CM. An electrochemical detection scheme for identification of single nucleotide polymorphisms using hairpin-forming probes. Nucleic Acids Res 2002; 30(12):e55.; 17. Hung K, Sun X, Ding H, Kalafatis M, Simioni P, Guo B. A matrix-assisted laser desorption/ionization time-of-flight based method for screening the 1691G --> A mutation in the factor V gene. Blood Coagul Fibrinolysis 2002; 13(2):117–22.; 18. Ozkan D, Erdem A, Kara P et al. Allele-specific genotype detection of factor V Leiden mutation from polymerase chain reaction amplicons based on label-free electrochemical genosensor. Anal Chem 2002; 74(23):5931–6.; 19. Alsmadi OA, Bornarth CJ, Song W et al. High accuracy genotyping directly from genomic DNA using a rolling circle amplification based assay. BMC Genomics 2003; 4(1):21.; 20. Cooper PC, Cooper SM, Smith JM, Kitchen S, Makris M. Evaluation of the Roche LightCycler: a simple and rapid method for direct detection of factor V Leiden and prothrombin G20210A genotypes from blood samples without the need for DNA extraction. Blood Coagul Fibrinolysis 2003; 14(5):499–503.; 21. El Housni H, Heimann P, Parma J, Vassart G. Single-nucleotide polymorphism genotyping by melting analysis of dual-labeled probes: examples using factor V Leiden and prothrombin 20210A mutations. Clin Chem 2003; 49(10):1669–72.; 22. Moser MJ, Marshall DJ, Grenier JK et al. Exploiting the enzymatic recognition of an unnatural base pair to develop a universal genetic analysis system. Clin Chem 2003; 49(3):407–14.; 23. Murphy K, Hafez M, Philips J, Yarnell K, Gutshall K, Berg K. Evaluation of temperature gradient capillary electrophoresis for detection of the Factor V Leiden mutation: coincident identification of a novel polymorphism in Factor V. Mol Diagn 2003; 7(1):35–40.; 24. Ozsoz M, Erdem A, Kerman K et al. Electrochemical genosensor based on colloidal gold nanoparticles for the detection of Factor V Leiden mutation using disposable pencil graphite electrodes. Anal Chem 2003; 75(9):2181–7.; 25. Schroell-Metzger B, Dicato M, Bosseler M, Berchem G. Comparison of standard PCR and the LightCycler technique to determine the thrombophilic mutations: an efficiency and cost study. Clin Chem Lab Med 2003; 41(4):482–5.; 26. Simundic AM, Topic E, Stefanovic M. Detection of factor V Leiden by PCR-SSCP using GMA precast Elchrom scientific gels. Clin Appl Thromb Hemost 2003; 9(3):227–31.; 27. Vaughn CP, Elenitoba-Johnson KS. Hybridization-induced dequenching of fluorescein-labeled oligonucleotides: a novel strategy for PCR detection and genotyping. Am J Pathol 2003; 163(1):29–35.; 28. Behrens M, Lange R. A highly reproducible and economically competitive SNP analysis of several well characterized human mutations. Clin Lab 2004; 50(5–6):305–16.; 29. French C, Li C, Strom C et al. Detection of the factor V Leiden mutation by a modified photo-cross-linking oligonucleotide hybridization assay. Clin Chem 2004; 50(2):296–305.; 30. Liew M, Pryor R, Palais R et al. Genotyping of single-nucleotide polymorphisms by high-resolution melting of small amplicons. Clin Chem 2004; 50(7):1156–64.; 31. Louis M, Dekairelle AF, Gala JL. Rapid combined genotyping of factor V, prothrombin and methylenetetrahydrofolate reductase single nucleotide polymorphisms using minor groove binding DNA oligonucleotides (MGB probes) and real-time polymerase chain reaction. Clin Chem Lab Med 2004; 42(12):1364–9.; 32. Angeline T, Bentley HA, Hawk AB et al. Prevalence of the Factor V G1691A and the Factor II/prothrombin G20210A gene polymorphisms among Tamilians. Exp Mol Pathol 2005; 79(1):9–13.; 33. Castley A, Higgins M, Ivey J, Mamotte C, Sayer DC, Christiansen FT. Clinical applications of whole-blood PCR with real-time instrumentation. Clin Chem 2005; 51(11):2025–30.; 34. Mammo L, Sheereen A, Saour T, Saour J. Comparative study between the Light Cycler and the PCR-restriction fragment length polymorphism in detecting factor V Leiden and factor II 20210G>A mutations. Clin Biochem 2006; 39(7):767–9.; 35. Bravo-Osorio M, Bydlowski SP. Detection of methylenetetrahydrofolate reductase (MTHFR) C677T and prothrombin G20210A mutations: second restriction site for digestion control of PCR products. Clin Chim Acta 2000; 301(1–2):219–23.; 36. Happich D, Madlener K, Schwaab R, Hanfland P, Potzsch B. Application of the TaqMan-PCR for genotyping of the prothrombin G20210A mutation and of the thermolabile methylenetetrahydrofolate reductase mutation. Thromb Haemost 2000; 84(1):144–5.; 37. Meyer M, Kutscher G, Vogel G. The prothrombin nt20210 A allele as a risk factor for venous thromboembolism: detection of heterozygous and homozygous carriers by alternative methods. Thromb Res 2000; 97(5):359–63.; 38. Gellings A, Holzem G, Wielckens K, Klingler KR. Prothrombin mutation: Employing the electrochemiluminescence technology of the elecsys(registered trademark) system for the detection of the point mutation at position 20210 in the 3′ untranslated region of the prothrombin gene: PROTHROMBIN MUTATION: VERWENDUNG DER ELEKTROCHEMILUMINESZENZTECHNOLOGIE DES ELECSYS(registered trademark) SYSTEMS ZUR DETEKTION DER PUNKTMUTATION AN DER POSITION 20210 IN DER 3′ UNTRANSLATIERTEN. LaboratoriumsMedizin 2001; 25(1–2):26–30.; 39. Gilchrist A, Solomon N, Erickson D et al. Automated detection of the G20210A prothrombin mutation using the LCx microparticle enzyme immunoassay. Clin Chim Acta 2001; 314(1–2):249–54.; 40. Hessner MJ, Friedman KD, Voelkerding KV et al. Multisite study for genotyping of the factor II (prothrombin) G20210A mutation by the invader assay. Clin Chem 2001; 47(11):2048–50.; 41. Huber S, McMaster KJ, Voelkerding KV. Analytical evaluation of primer engineered multiplex polymerase chain reaction-restriction fragment length polymorphism for detection of factor V Leiden and prothrombin G20210A. J Mol Diagn 2000; 2(3):153–7.; 42. Leyte A, Smits PH, van Straalen JP, van Doorn LJ, Quint WG. Automated, simultaneous detection of the factor V Leiden and prothrombin (G20210A) variants using multiplex PCR and a line probe assay. Thromb Haemost 2000; 83(2):354–5.; 43. van den Bergh FA, van Oeveren-Dybicz AM, Bon MA. Rapid single-tube genotyping of the factor V Leiden and prothrombin mutations by real-time PCR using dual-color detection. Clin Chem 2000; 46(8 Pt 1):1191–5.; 44. DelRio-LaFreniere SA, McGlennen RC. Simultaneous allele-specific amplification: a strategy using modified primer-template mismatches for SNP detection--application to prothrombin 20210A (factor II) and factor V Leiden (1691A) gene mutations. Mol Diagn 2001; 6(3):201–9.; 45. Endler G, Kyrle PA, Eichinger S, Exner M, Mannhalter C. Multiplexed mutagenically separated PCR: simultaneous single-tube detection of the factor V R506Q (G1691A), the prothrombin G20210A, and the methylenetetrahydrofolate reductase A223V (C677T) variants. Clin Chem 2001; 47(2):333–5.; 46. Ameziane N, Lamotte M, Lamoril J et al. Combined factor V leiden (G1691A) and prothrombin (G20210A) genotyping by multiplex real-time polymerase chain reaction using fluorescent resonance energy transfer hybridization probes on the Rotor-Gene 2000. Blood Coagul Fibrinolysis 2003; 14(4):421–4.; 47. Erali M, Schmidt B, Lyon E, Wittwer C. Evaluation of electronic microarrays for genotyping factor V, factor II, and MTHFR. Clin Chem 2003; 49(5):732–9.; 48. Lucotte G, Champenois T. Duplex PCR-RFLP for simultaneous detection of factor V Leiden and prothrombin G20210A. Mol Cell Probes 2003; 17(5):267–9.; 49. Neitzel B, Matern C, Holinski-Feder E. Easy, accurate and reliable screening for SNPs by ion pair/reverse phase HPLC: simultaneous detection of factor V G1691A, prothrombin G20210A and methylenetetrahydrofolate reductase C677T variants. Clin Lab 2003; 49(7–8):313–8.; 50. Schrijver I, Lay MJ, Zehnder JL. Diagnostic single nucleotide polymorphism analysis of factor V Leiden and prothrombin 20210G > A. A comparison of the Nanogen Eelectronic Microarray with restriction enzyme digestion and the Roche LightCycler. Am J Clin Pathol 2003; 119(4):490–6.; 51. Baris I, Koksal V, Etlik O. Multiplex PCR-RFLP assay for detection of factor V Leiden and prothrombin G20210A. Genet Test 2004; 8(4):381–3.; 52. Carmi N, Cohen D, Zvang E, Naparstek E, Deutsch V. Pronto ThromboRisk--a novel primer-extension ELISA based assay for the detection of mutations associated with increased risk for thrombophilia. J Clin Lab Anal 2004; 18(5):259–64.; 53. Patnaik M, Dlott JS, Fontaine RN et al. Detection of genomic polymorphisms associated with venous thrombosis using the invader biplex assay. J Mol Diagn 2004; 6(2):137–44.; 54. Ugozzoli LA, Hamby K. Four-color multiplex 5′ nuclease assay for the simultaneous detection of the factor V Leiden and the prothrombin G20210A mutations. Mol Cell Probes 2004; 18(3):161–6.; 55. Hobson-Peters J, Toye P. A whole-blood homogeneous assay for the multiplex detection of the factor V G1691A and the prothrombin G20210A mutations. Mol Cell Probes 2005; 19(4):290–7.; 56. Koksal V, Baris I, Etlik O. Primer-engineered multiplex PCR-RFLP for detection of MTHFR C677T, prothrombin G20210A and factor V Leiden mutations. Exp Mol Pathol 2007; 83(1):1–3.; 57. Lopez M, Giraldo P, Alvarez P et al. Multiplex assay for genetic testing of thrombophilia: a method for routine clinical care. J Clin Lab Anal 2007; 21(6):349–55.; 58. Hertzberg M, Neville S, Favaloro E, McDonald D. External quality assurance of DNA testing for thrombophilia mutations. Am J Clin Pathol 2005; 123(2):189–93.; 59. Jennings I, Kitchen S, Woods TA, Preston FE. Multilaboratory testing in thrombophilia through the United Kingdom National External Quality Assessment Scheme (Blood Coagulation) Quality Assurance Program. Semin Thromb Hemost 2005; 31(1):66–72.; 60. Tripodi A, Chantarangkul V, Menegatti M, Tagliabue L, Peyvandi F. Performance of clinical laboratories for DNA analyses to detect thrombophilia mutations. Clin Chem 2005; 51(7):1310–1.

Evidence Table 2 Results of tests for detection of factor V leiden

TABLE NOT AVAILABLE

Reference List
1. Hertzberg M, Neville S, Favaloro E, McDonald D. External quality assurance of DNA testing for thrombophilia mutations. Am J Clin Pathol 2005; 123(2):189–93.; 2. Jennings I, Kitchen S, Woods TA, Preston FE. Multilaboratory testing in thrombophilia through the United Kingdom National External Quality Assessment Scheme (Blood Coagulation) Quality Assurance Program. Semin Thromb Hemost 2005; 31(1):66–72.; 3. Angeline T, Bentley HA, Hawk AB et al. Prevalence of the Factor V G1691A and the Factor II/prothrombin G20210A gene polymorphisms among Tamilians. Exp Mol Pathol 2005; 79(1):9–13.; 4. Nauck M, Marz W, Wieland H. Evaluation of the Roche diagnostics LightCycler-Factor V Leiden Mutation Detection Kit and the LightCycler-Prothrombin Mutation Detection Kit. Clin Biochem 2000; 33(3):213–6.; 5. Parks SB, Popovich BW, Press RD. Real-time polymerase chain reaction with fluorescent hybridization probes for the detection of prevalent mutations causing common thrombophilic and iron overload phenotypes. Am J Clin Pathol 2001; 115(3):439–47.; 6. Ledford M, Friedman KD, Hessner MJ, Moehlenkamp C, Williams TM, Larson RS. A multi-site study for detection of the factor V (Leiden) mutation from genomic DNA using a homogeneous invader microtiter plate fluorescence resonance energy transfer (FRET) assay. J Mol Diagn 2000; 2(2):97–104.; 7. Moser MJ, Marshall DJ, Grenier JK et al. Exploiting the enzymatic recognition of an unnatural base pair to develop a universal genetic analysis system. Clin Chem 2003; 49(3):407–14.; 8. Castley A, Higgins M, Ivey J, Mamotte C, Sayer DC, Christiansen FT. Clinical applications of whole-blood PCR with real-time instrumentation. Clin Chem 2005; 51(11):2025–30.; 9. Hessner MJ, Budish MA, Friedman KD. Genotyping of factor V G1691A (Leiden) without the use of PCR by invasive cleavage of oligonucleotide probes. Clin Chem 2000; 46(8 Pt 1):1051–6.; 10. Cooper PC, Cooper SM, Smith JM, Kitchen S, Makris M. Evaluation of the Roche LightCycler: a simple and rapid method for direct detection of factor V Leiden and prothrombin G20210A genotypes from blood samples without the need for DNA extraction. Blood Coagul Fibrinolysis 2003; 14(5):499–503.; 11. Schroell-Metzger B, Dicato M, Bosseler M, Berchem G. Comparison of standard PCR and the LightCycler technique to determine the thrombophilic mutations: an efficiency and cost study. Clin Chem Lab Med 2003; 41(4):482–5.; 12. Liew M, Pryor R, Palais R et al. Genotyping of single-nucleotide polymorphisms by high-resolution melting of small amplicons. Clin Chem 2004; 50(7):1156–64.; 13. Sanders Sevall J. Factor V Leiden genotyping using real-time fluorescent polymerase chain reaction. Mol Cell Probes 2000; 14(4):249–53.; 14. Behrens M, Lange R. A highly reproducible and economically competitive SNP analysis of several well characterized human mutations. Clin Lab 2004; 50(5–6):305–16.; 15. Louis M, Dekairelle AF, Gala JL. Rapid combined genotyping of factor V, prothrombin and methylenetetrahydrofolate reductase single nucleotide polymorphisms using minor groove binding DNA oligonucleotides (MGB probes) and real-time polymerase chain reaction. Clin Chem Lab Med 2004; 42(12):1364–9.; 16. Benson JM, Ellingsen D, El-Jamil M et al. Factor V Leiden and factor V R2 allele: high-throughput analysis and association with venous thromboembolism. Thromb Haemost 2001; 86(5):1188–92.; 17. Murphy K, Hafez M, Philips J, Yarnell K, Gutshall K, Berg K. Evaluation of temperature gradient capillary electrophoresis for detection of the Factor V Leiden mutation: coincident identification of a novel polymorphism in Factor V. Mol Diagn 2003; 7(1):35–40.; 18. Ozkan D, Erdem A, Kara P et al. Allele-specific genotype detection of factor V Leiden mutation from polymerase chain reaction amplicons based on label-free electrochemical genosensor. Anal Chem 2002; 74(23):5931–6.; 19. Huang TJ, Liu M, Knight LD, Grody WW, Miller JF, Ho CM. An electrochemical detection scheme for identification of single nucleotide polymorphisms using hairpin-forming probes. Nucleic Acids Res 2002; 30(12):e55.; 20. Ozsoz M, Erdem A, Kerman K et al. Electrochemical genosensor based on colloidal gold nanoparticles for the detection of Factor V Leiden mutation using disposable pencil graphite electrodes. Anal Chem 2003; 75(9):2181–7.; 21. Humeny A, Bonk T, Berkholz A, Wildt L, Becker CM. Genotyping of thrombotic risk factors by MALDI-TOF mass spectrometry. Clin Biochem 2001; 34(7):531–6.; 22. Hung K, Sun X, Ding H, Kalafatis M, Simioni P, Guo B. A matrix-assisted laser desorption/ionization time-of-flight based method for screening the 1691G --> A mutation in the factor V gene. Blood Coagul Fibrinolysis 2002; 13(2):117–22.; 23. Pecheniuk NM, Marsh NA, Walsh TP. Multiple analysis of three common genetic alterations associated with thrombophilia. Blood Coagul Fibrinolysis 2000; 11(2):183–9.; 24. Potter CG, Liu YT, Rees DC. Factor V Leiden mutation screened by PCR and detected with lanthanide-labeled probes. Genet Test 2001; 5(4):291–7.; 25. Mammo L, Sheereen A, Saour T, Saour J. Comparative study between the Light Cycler and the PCR-restriction fragment length polymorphism in detecting factor V Leiden and factor II 20210G>A mutations. Clin Biochem 2006; 39(7):767–9.; 26. El Housni H, Heimann P, Parma J, Vassart G. Single-nucleotide polymorphism genotyping by melting analysis of dual-labeled probes: examples using factor V Leiden and prothrombin 20210A mutations. Clin Chem 2003; 49(10):1669–72.; 27. Alsmadi OA, Bornarth CJ, Song W et al. High accuracy genotyping directly from genomic DNA using a rolling circle amplification based assay. BMC Genomics 2003; 4(1):21.; 28. Tsongalis GJ, Rainey BJ, Hodges KA. READIT: a novel technology used in the interrogation of nucleic acid sequences for single-nucleotide polymorphisms. Exp Mol Pathol 2001; 71(3):222–5.; 29. Kowalski A, Radu D, Gold B. Colorimetric microwell plate detection of the factor V Leiden mutation. Clin Chem 2000; 46(8 Pt 1):1195–8.; 30. Simundic AM, Topic E, Stefanovic M. Detection of factor V Leiden by PCR-SSCP using GMA precast Elchrom scientific gels. Clin Appl Thromb Hemost 2003; 9(3):227–31.; 31. Reyes AA, Ugozzoli LA, Lowery JD et al. Linked linear amplification: a new method for the amplification of DNA. Clin Chem 2001; 47(1):31–40.; 32. Evans JG, Lee-Tataseo C. Determination of the factor V Leiden single-nucleotide polymorphism in a commercial clinical laboratory by use of NanoChip microelectronic array technology. Clin Chem 2002; 48(9):1406–11.; 33. Crockett AO, Wittwer CT. Fluorescein-labeled oligonucleotides for real-time pcr: using the inherent quenching of deoxyguanosine nucleotides. Anal Biochem 2001; 290(1):89–97.; 34. Vaughn CP, Elenitoba-Johnson KS. Hybridization-induced dequenching of fluorescein-labeled oligonucleotides: a novel strategy for PCR detection and genotyping. Am J Pathol 2003; 163(1):29–35.; 35. Tripodi A, Chantarangkul V, Menegatti M, Tagliabue L, Peyvandi F. Performance of clinical laboratories for DNA analyses to detect thrombophilia mutations. Clin Chem 2005; 51(7):1310–1.; 36. French C, Li C, Strom C et al. Detection of the factor V Leiden mutation by a modified photo-cross-linking oligonucleotide hybridization assay. Clin Chem 2004; 50(2):296–305.; 37. Rhodes RB, Lewis K, Shultz J et al. Analysis of the factor V Leiden mutation using the READIT Assay. Mol Diagn 2001; 6(1):55–61.

Evidence Table 3 Results of tests for detection of prothrombin G20210A

TABLE NOT AVAILABLE

Reference List
1. Hertzberg M, Neville S, Favaloro E, McDonald D. External quality assurance of DNA testing for thrombophilia mutations. Am J Clin Pathol 2005; 123(2):189–93.; 2. Jennings I, Kitchen S, Woods TA, Preston FE. Multilaboratory testing in thrombophilia through the United Kingdom National External Quality Assessment Scheme (Blood Coagulation) Quality Assurance Program. Semin Thromb Hemost 2005; 31(1):66–72.; 3. Angeline T, Bentley HA, Hawk AB et al. Prevalence of the Factor V G1691A and the Factor II/prothrombin G20210A gene polymorphisms among Tamilians. Exp Mol Pathol 2005; 79(1):9–13.; 4. Bravo-Osorio M, Bydlowski SP. Detection of methylenetetrahydrofolate reductase (MTHFR) C677T and prothrombin G20210A mutations: second restriction site for digestion control of PCR products. Clin Chim Acta 2000; 301(1–2):219–23.; 5. Nauck M, Marz W, Wieland H. Evaluation of the Roche diagnostics LightCycler-Factor V Leiden Mutation Detection Kit and the LightCycler-Prothrombin Mutation Detection Kit. Clin Biochem 2000; 33(3):213–6.; 6. Parks SB, Popovich BW, Press RD. Real-time polymerase chain reaction with fluorescent hybridization probes for the detection of prevalent mutations causing common thrombophilic and iron overload phenotypes. Am J Clin Pathol 2001; 115(3):439–47.; 7. Hessner MJ, Friedman KD, Voelkerding KV et al. Multisite study for genotyping of the factor II (prothrombin) G20210A mutation by the invader assay. Clin Chem 2001; 47(11):2048–50.; 8. Moser MJ, Marshall DJ, Grenier JK et al. Exploiting the enzymatic recognition of an unnatural base pair to develop a universal genetic analysis system. Clin Chem 2003; 49(3):407–14.; 9. Castley A, Higgins M, Ivey J, Mamotte C, Sayer DC, Christiansen FT. Clinical applications of whole-blood PCR with real-time instrumentation. Clin Chem 2005; 51(11):2025–30.; 10. Cooper PC, Cooper SM, Smith JM, Kitchen S, Makris M. Evaluation of the Roche LightCycler: a simple and rapid method for direct detection of factor V Leiden and prothrombin G20210A genotypes from blood samples without the need for DNA extraction. Blood Coagul Fibrinolysis 2003; 14(5):499–503.; 11. Schroell-Metzger B, Dicato M, Bosseler M, Berchem G. Comparison of standard PCR and the LightCycler technique to determine the thrombophilic mutations: an efficiency and cost study. Clin Chem Lab Med 2003; 41(4):482–5.; 12. Liew M, Pryor R, Palais R et al. Genotyping of single-nucleotide polymorphisms by high-resolution melting of small amplicons. Clin Chem 2004; 50(7):1156–64.; 13. Behrens M, Lange R. A highly reproducible and economically competitive SNP analysis of several well characterized human mutations. Clin Lab 2004; 50(5–6):305–16.; 14. Louis M, Dekairelle AF, Gala JL. Rapid combined genotyping of factor V, prothrombin and methylenetetrahydrofolate reductase single nucleotide polymorphisms using minor groove binding DNA oligonucleotides (MGB probes) and real-time polymerase chain reaction. Clin Chem Lab Med 2004; 42(12):1364–9.; 15. Happich D, Madlener K, Schwaab R, Hanfland P, Potzsch B. Application of the TaqMan-PCR for genotyping of the prothrombin G20210A mutation and of the thermolabile methylenetetrahydrofolate reductase mutation. Thromb Haemost 2000; 84(1):144–5.; 16. Gellings A, Holzem G, Wielckens K, Klingler KR. Prothrombin mutation: Employing the electrochemiluminescence technology of the elecsys(registered trademark) system for the detection of the point mutation at position 20210 in the 3′ untranslated region of the prothrombin gene: PROTHROMBIN MUTATION: VERWENDUNG DER ELEKTROCHEMILUMINESZENZTECHNOLOGIE DES ELECSYS(registered trademark) SYSTEMS ZUR DETEKTION DER PUNKTMUTATION AN DER POSITION 20210 IN DER 3′ UNTRANSLATIERTEN. LaboratoriumsMedizin 2001; 25(1–2):26–30.; 17. Humeny A, Bonk T, Berkholz A, Wildt L, Becker CM. Genotyping of thrombotic risk factors by MALDI-TOF mass spectrometry. Clin Biochem 2001; 34(7):531–6.; 18. Gilchrist A, Solomon N, Erickson D et al. Automated detection of the G20210A prothrombin mutation using the LCx microparticle enzyme immunoassay. Clin Chim Acta 2001; 314(1–2):249–54.; 19. Pecheniuk NM, Marsh NA, Walsh TP. Multiple analysis of three common genetic alterations associated with thrombophilia. Blood Coagul Fibrinolysis 2000; 11(2):183–9.; 20. Mammo L, Sheereen A, Saour T, Saour J. Comparative study between the Light Cycler and the PCR-restriction fragment length polymorphism in detecting factor V Leiden and factor II 20210G>A mutations. Clin Biochem 2006; 39(7):767–9.; 21. El Housni H, Heimann P, Parma J, Vassart G. Single-nucleotide polymorphism genotyping by melting analysis of dual-labeled probes: examples using factor V Leiden and prothrombin 20210A mutations. Clin Chem 2003; 49(10):1669–72.; 22. Alsmadi OA, Bornarth CJ, Song W et al. High accuracy genotyping directly from genomic DNA using a rolling circle amplification based assay. BMC Genomics 2003; 4(1):21.; 23. Tripodi A, Chantarangkul V, Menegatti M, Tagliabue L, Peyvandi F. Performance of clinical laboratories for DNA analyses to detect thrombophilia mutations. Clin Chem 2005; 51(7):1310–1.; 24. Meyer M, Kutscher G, Vogel G. The prothrombin nt20210 A allele as a risk factor for venous thromboembolism: detection of heterozygous and homozygous carriers by alternative methods. Thromb Res 2000; 97(5):359–63.

Evidence Table 4 Results of tests for detection of simultaneous mutations

TABLE NOT AVAILABLE

Reference List
1. Neitzel B, Matern C, Holinski-Feder E. Easy, accurate and reliable screening for SNPs by ion pair/reverse phase HPLC: simultaneous detection of factor V G1691A, prothrombin G20210A and methylenetetrahydrofolate reductase C677T variants. Clin Lab 2003; 49(7–8):313–8.; 2. Huber S, McMaster KJ, Voelkerding KV. Analytical evaluation of primer engineered multiplex polymerase chain reaction-restriction fragment length polymorphism for detection of factor V Leiden and prothrombin G20210A. J Mol Diagn 2000; 2(3):153–7.; 3. Lucotte G, Champenois T. Duplex PCR-RFLP for simultaneous detection of factor V Leiden and prothrombin G20210A. Mol Cell Probes 2003; 17(5):267–9.; 4. Koksal V, Baris I, Etlik O. Primer-engineered multiplex PCR-RFLP for detection of MTHFR C677T, prothrombin G20210A and factor V Leiden mutations. Exp Mol Pathol 2007; 83(1):1–3.; 5. Baris I, Koksal V, Etlik O. Multiplex PCR-RFLP assay for detection of factor V Leiden and prothrombin G20210A. Genet Test 2004; 8(4):381–3.; 6. DelRio-LaFreniere SA, McGlennen RC. Simultaneous allele-specific amplification: a strategy using modified primer-template mismatches for SNP detection--application to prothrombin 20210A (factor II) and factor V Leiden (1691A) gene mutations. Mol Diagn 2001; 6(3):201–9.; 7. Ameziane N, Lamotte M, Lamoril J et al. Combined factor V leiden (G1691A) and prothrombin (G20210A) genotyping by multiplex real-time polymerase chain reaction using fluorescent resonance energy transfer hybridization probes on the Rotor-Gene 2000. Blood Coagul Fibrinolysis 2003; 14(4):421–4.; 8. Hobson-Peters J, Toye P. A whole-blood homogeneous assay for the multiplex detection of the factor V G1691A and the prothrombin G20210A mutations. Mol Cell Probes 2005; 19(4):290–7.; 9. van den Bergh FA, van Oeveren-Dybicz AM, Bon MA. Rapid single-tube genotyping of the factor V Leiden and prothrombin mutations by real-time PCR using dual-color detection. Clin Chem 2000; 46(8 Pt 1):1191–5.; 10. Patnaik M, Dlott JS, Fontaine RN et al. Detection of genomic polymorphisms associated with venous thrombosis using the invader biplex assay. J Mol Diagn 2004; 6(2):137–44.; 11. Carmi N, Cohen D, Zvang E, Naparstek E, Deutsch V. Pronto ThromboRisk--a novel primer-extension ELISA based assay for the detection of mutations associated with increased risk for thrombophilia. J Clin Lab Anal 2004; 18(5):259–64.; 12. Lopez M, Giraldo P, Alvarez P et al. Multiplex assay for genetic testing of thrombophilia: a method for routine clinical care. J Clin Lab Anal 2007; 21(6):349–55.; 13. Ugozzoli LA, Hamby K. Four-color multiplex 5′ nuclease assay for the simultaneous detection of the factor V Leiden and the prothrombin G20210A mutations. Mol Cell Probes 2004; 18(3):161–6.; 14. Endler G, Kyrle PA, Eichinger S, Exner M, Mannhalter C. Multiplexed mutagenically separated PCR: simultaneous single-tube detection of the factor V R506Q (G1691A), the prothrombin G20210A, and the methylenetetrahydrofolate reductase A223V (C677T) variants. Clin Chem 2001; 47(2):333–5.; 15. Leyte A, Smits PH, van Straalen JP, van Doorn LJ, Quint WG. Automated, simultaneous detection of the factor V Leiden and prothrombin (G20210A) variants using multiplex PCR and a line probe assay. Thromb Haemost 2000; 83(2):354–5.; 16. Schrijver I, Lay MJ, Zehnder JL. Diagnostic single nucleotide polymorphism analysis of factor V Leiden and prothrombin 20210G > A. A comparison of the Nanogen Eelectronic Microarray with restriction enzyme digestion and the Roche LightCycler. Am J Clin Pathol 2003; 119(4):490–6.; 17. Erali M, Schmidt B, Lyon E, Wittwer C. Evaluation of electronic microarrays for genotyping factor V, factor II, and MTHFR. Clin Chem 2003; 49(5):732–9.; 18. Verri A, Focher F, Tettamanti G, Grazioli V. Two-step genetic screening of thrombophilia by pyrosequencing. Clin Chem 2005; 51(7):1282–4.

Evidence Table 5 Quality and applicability of studies addressing Factor V Leiden and Recurrent Venous Thrombosis in Probands

TABLE NOT AVAILABLE

Reference List
1. Ridker PM, Miletich JP, Stampfer MJ, Goldhaber SZ, Lindpaintner K, Hennekens CH. Factor V Leiden and risks of recurrent idiopathic venous thromboembolism. Circulation 1995; 92(10):2800–2.; 2. Kearon C, Gent M, Hirsh J et al. A comparison of three months of anticoagulation with extended anticoagulation for a first episode of idiopathic venous thromboembolism. N Engl J Med 1999; 340(12):901–7.; 3. Lindmarker P, Schulman S, Sten-Linder M, Wiman B, Egberg N, Johnsson H. The risk of recurrent venous thromboembolism in carriers and non-carriers of the G1691A allele in the coagulation factor V gene and the G20210A allele in the prothrombin gene. DURAC Trial Study Group. Duration of Anticoagulation. Thromb Haemost 1999; 81(5):684–9.; 4. Simioni P, Prandoni P, Lensing AW et al. Risk for subsequent venous thromboembolic complications in carriers of the prothrombin or the factor V gene mutation with a first episode of deep-vein thrombosis. Blood 2000; 96(10):3329–33.; 5. Hoibraaten E, Mowinckel MC, de Ronde H, Bertina RM, Sandset PM. Hormone replacement therapy and acquired resistance to activated protein C: results of a randomized, double-blind, placebo-controlled trial. Br J Haematol 2001; 115(2):415–20.; 6. Miles JS, Miletich JP, Goldhaber SZ, Hennekens CH, Ridker PM. G20210A mutation in the prothrombin gene and the risk of recurrent venous thromboembolism. J Am Coll Cardiol 2001; 37(1):215–8.; 7. Eichinger S, Weltermann A, Mannhalter C et al. The risk of recurrent venous thromboembolism in heterozygous carriers of factor V Leiden and a first spontaneous venous thromboembolism. Arch Intern Med 2002; 162(20):2357–60.; 8. Baglin T, Luddington R, Brown K, Baglin C. Incidence of recurrent venous thromboembolism in relation to clinical and thrombophilic risk factors: prospective cohort study. Lancet 2003; 362(9383):523–6.; 9. Is recurrent venous thromboembolism more frequent in homozygous patients for the factor V Leiden mutation than in heterozygous patients? Blood Coagul Fibrinolysis 2003; 14(6):523–9.; Notes: CORPORATE NAME: Procare Group; 10. Palareti G, Legnani C, Cosmi B et al. Predictive value of D-dimer test for recurrent venous thromboembolism after anticoagulation withdrawal in subjects with a previous idiopathic event and in carriers of congenital thrombophilia. Circulation 2003; 108(3):313–8.; 11. Baarslag HJ, Koopman MM, Hutten BA et al. Long-term follow-up of patients with suspected deep vein thrombosis of the upper extremity: survival, risk factors and post-thrombotic syndrome. Eur J Intern Med 2004; 15(8):503–7.; 12. Kyrle PA, Minar E, Bialonczyk C, Hirschl M, Weltermann A, Eichinger S. The risk of recurrent venous thromboembolism in men and women. N Engl J Med 2004; 350(25):2558–63.; 13. Christiansen SC, Cannegieter SC, Koster T, Vandenbroucke JP, Rosendaal FR. Thrombophilia, clinical factors, and recurrent venous thrombotic events. JAMA 2005; 293(19):2352–61.; 14. Mansilha A, Araujo F, Severo M, Sampaio SM, Toledo T, Albuquerque R. Genetic polymorphisms and risk of recurrent deep venous thrombosis in young people: prospective cohort study. Eur J Vasc Endovasc Surg 2005; 30(5):545–9.; 15. Santamaria MG, Agnelli G, Taliani MR et al. Thrombophilic abnormalities and recurrence of venous thromboembolism in patients treated with standardized anticoagulant treatment. Thromb Res 2005; 116(4):301–6.; Notes: CORPORATE NAME: Warfarin Optimal Duration Italian Trial (WODIT) Investigators; 16. Vossen CY, Walker ID, Svensson P et al. Recurrence rate after a first venous thrombosis in patients with familial thrombophilia. Arterioscler Thromb Vasc Biol 2005; 25(9):1992–7.; 17. Gonzalez-Porras JR, Garcia-Sanz R, Alberca I et al. Risk of recurrent venous thrombosis in patients with G20210A mutation in the prothrombin gene or factor V Leiden mutation. Blood Coagul Fibrinolysis 2006; 17(1):23–8.; 18. Hron G, Eichinger S, Weltermann A et al. Family history for venous thromboembolism and the risk for recurrence. Am J Med 2006; 119(1):50–3.; 19. Wahlander K, Eriksson H, Lundstrom T et al. Risk of recurrent venous thromboembolism or bleeding in relation to thrombophilic risk factors in patients receiving ximelagatran or placebo for long-term secondary prevention of venous thromboembolism. Br J Haematol 2006; 133(1):68–77.; Notes: CORPORATE NAME: THRIVE III Investigators; 20. Prandoni P, Noventa F, Ghirarduzzi A et al. The risk of recurrent venous thromboembolism after discontinuing anticoagulation in patients with acute proximal deep vein thrombosis or pulmonary embolism. A prospective cohort study in 1,626 patients. Haematologica 2007; 92(2):199–205.; 21. Strandberg K, Svensson PJ, Ohlin AK. Venous thromboembolism in carriers of the Factor V Leiden mutation and in patients without known thrombophilic risk factor; prediction of recurrence and APC-PCI complex concentration and/or soluble thrombomodulin antigen and activity. Thromb Res 2007; 121(2):145–51.; 22. Kearon C, Julian JA, Kovacs MJ et al. Influence of thrombophilia on risk of recurrent venous thromboembolism while on warfarin: Results from a randomized trial. Blood 2008.; 23. Eichinger S, Minar E, Hirschl M et al. The risk of early recurrent venous thromboembolism after oral anticoagulant therapy in patients with the G20210A transition in the prothrombin gene. Thromb Haemost 1999; 81(1):14–7.

Evidence Table 6 Results for Probands Heterozygous for the Factor V Leiden Mutation

TABLE NOT AVAILABLE

Reference List
1. Gonzalez-Porras JR, Garcia-Sanz R, Alberca I et al. Risk of recurrent venous thrombosis in patients with G20210A mutation in the prothrombin gene or factor V Leiden mutation. Blood Coagul Fibrinolysis 2006; 17(1):23–8.; 2. Wahlander K, Eriksson H, Lundstrom T et al. Risk of recurrent venous thromboembolism or bleeding in relation to thrombophilic risk factors in patients receiving ximelagatran or placebo for long-term secondary prevention of venous thromboembolism. Br J Haematol 2006; 133(1):68–77.; Notes: CORPORATE NAME: THRIVE III Investigators; 3. Is recurrent venous thromboembolism more frequent in homozygous patients for the factor V Leiden mutation than in heterozygous patients? Blood Coagul Fibrinolysis 2003; 14(6):523–9.; Notes: CORPORATE NAME: Procare Group; 4. Palareti G, Legnani C, Cosmi B et al. Predictive value of D-dimer test for recurrent venous thromboembolism after anticoagulation withdrawal in subjects with a previous idiopathic event and in carriers of congenital thrombophilia. Circulation 2003; 108(3):313–8.; 5. Eichinger S, Weltermann A, Mannhalter C et al. The risk of recurrent venous thromboembolism in heterozygous carriers of factor V Leiden and a first spontaneous venous thromboembolism. Arch Intern Med 2002; 162(20):2357–60.; 6. Hoibraaten E, Mowinckel MC, de Ronde H, Bertina RM, Sandset PM. Hormone replacement therapy and acquired resistance to activated protein C: results of a randomized, double-blind, placebo-controlled trial. Br J Haematol 2001; 115(2):415–20.; 7. Miles JS, Miletich JP, Goldhaber SZ, Hennekens CH, Ridker PM. G20210A mutation in the prothrombin gene and the risk of recurrent venous thromboembolism. J Am Coll Cardiol 2001; 37(1):215–8.; 8. Simioni P, Prandoni P, Lensing AW et al. Risk for subsequent venous thromboembolic complications in carriers of the prothrombin or the factor V gene mutation with a first episode of deep-vein thrombosis. Blood 2000; 96(10):3329–33.; 9. Lindmarker P, Schulman S, Sten-Linder M, Wiman B, Egberg N, Johnsson H. The risk of recurrent venous thromboembolism in carriers and non-carriers of the G1691A allele in the coagulation factor V gene and the G20210A allele in the prothrombin gene. DURAC Trial Study Group. Duration of Anticoagulation. Thromb Haemost 1999; 81(5):684–9.; 10. Ridker PM, Miletich JP, Stampfer MJ, Goldhaber SZ, Lindpaintner K, Hennekens CH. Factor V Leiden and risks of recurrent idiopathic venous thromboembolism. Circulation 1995; 92(10):2800–2.; 11. Prandoni P, Noventa F, Ghirarduzzi A et al. The risk of recurrent venous thromboembolism after discontinuing anticoagulation in patients with acute proximal deep vein thrombosis or pulmonary embolism. A prospective cohort study in 1,626 patients. Haematologica 2007; 92(2):199–205.; 12. Kearon C, Gent M, Hirsh J et al. A comparison of three months of anticoagulation with extended anticoagulation for a first episode of idiopathic venous thromboembolism. N Engl J Med 1999; 340(12):901–7.; 13. Kearon C, Julian JA, Kovacs MJ et al. Influence of thrombophilia on risk of recurrent venous thromboembolism while on warfarin: Results from a randomized trial. Blood 2008.; 14. Christiansen SC, Cannegieter SC, Koster T, Vandenbroucke JP, Rosendaal FR. Thrombophilia, clinical factors, and recurrent venous thrombotic events. JAMA 2005; 293(19):2352–61.

Evidence Table 7 Results for probands homozygous for Factor V Leiden mutation

TABLE NOT AVAILABLE

Reference List
1. Wahlander K, Eriksson H, Lundstrom T et al. Risk of recurrent venous thromboembolism or bleeding in relation to thrombophilic risk factors in patients receiving ximelagatran or placebo for long-term secondary prevention of venous thromboembolism. Br J Haematol 2006; 133(1):68–77.; Notes: CORPORATE NAME: THRIVE III Investigators; 2. Is recurrent venous thromboembolism more frequent in homozygous patients for the factor V Leiden mutation than in heterozygous patients? Blood Coagul Fibrinolysis 2003; 14(6):523–9.; Notes: CORPORATE NAME: Procare Group; 3. Palareti G, Legnani C, Cosmi B et al. Predictive value of D-dimer test for recurrent venous thromboembolism after anticoagulation withdrawal in subjects with a previous idiopathic event and in carriers of congenital thrombophilia. Circulation 2003; 108(3):313–8.; 4. Hoibraaten E, Mowinckel MC, de Ronde H, Bertina RM, Sandset PM. Hormone replacement therapy and acquired resistance to activated protein C: results of a randomized, double-blind, placebo-controlled trial. Br J Haematol 2001; 115(2):415–20.; 5. Lindmarker P, Schulman S, Sten-Linder M, Wiman B, Egberg N, Johnsson H. The risk of recurrent venous thromboembolism in carriers and non-carriers of the G1691A allele in the coagulation factor V gene and the G20210A allele in the prothrombin gene. DURAC Trial Study Group. Duration of Anticoagulation. Thromb Haemost 1999; 81(5):684–9.; 6. Christiansen SC, Cannegieter SC, Koster T, Vandenbroucke JP, Rosendaal FR. Thrombophilia, clinical factors, and recurrent venous thrombotic events. JAMA 2005; 293(19):2352–61.; 7. Kearon C, Gent M, Hirsh J et al. A comparison of three months of anticoagulation with extended anticoagulation for a first episode of idiopathic venous thromboembolism. N Engl J Med 1999; 340(12):901–7.; 8. Kearon C, Julian JA, Kovacs MJ et al. Influence of thrombophilia on risk of recurrent venous thromboembolism while on warfarin: Results from a randomized trial. Blood 2008.

Evidence Table 8 Results for probands with unspecified Factor V Leiden mutations

TABLE NOT AVAILABLE

Reference List
1. Strandberg K, Svensson PJ, Ohlin AK. Venous thromboembolism in carriers of the Factor V Leiden mutation and in patients without known thrombophilic risk factor; prediction of recurrence and APC-PCI complex concentration and/or soluble thrombomodulin antigen and activity. Thromb Res 2007; 121(2):145–51.; 2. Hron G, Eichinger S, Weltermann A et al. Family history for venous thromboembolism and the risk for recurrence. Am J Med 2006; 119(1):50–3.; 3. Mansilha A, Araujo F, Severo M, Sampaio SM, Toledo T, Albuquerque R. Genetic polymorphisms and risk of recurrent deep venous thrombosis in young people: prospective cohort study. Eur J Vasc Endovasc Surg 2005; 30(5):545–9.; 4. Santamaria MG, Agnelli G, Taliani MR et al. Thrombophilic abnormalities and recurrence of venous thromboembolism in patients treated with standardized anticoagulant treatment. Thromb Res 2005; 116(4):301–6.; Notes: CORPORATE NAME: Warfarin Optimal Duration Italian Trial (WODIT) Investigators; 5. Vossen CY, Walker ID, Svensson P et al. Recurrence rate after a first venous thrombosis in patients with familial thrombophilia. Arterioscler Thromb Vasc Biol 2005; 25(9):1992–7.; 6. Baarslag HJ, Koopman MM, Hutten BA et al. Long-term follow-up of patients with suspected deep vein thrombosis of the upper extremity: survival, risk factors and post-thrombotic syndrome. Eur J Intern Med 2004; 15(8):503–7.; 7. Kyrle PA, Minar E, Bialonczyk C, Hirschl M, Weltermann A, Eichinger S. The risk of recurrent venous thromboembolism in men and women. N Engl J Med 2004; 350(25):2558–63.; 8. Baglin T, Luddington R, Brown K, Baglin C. Incidence of recurrent venous thromboembolism in relation to clinical and thrombophilic risk factors: prospective cohort study. Lancet 2003; 362(9383):523–6.

Evidence Table 9 Results for probands double heterozygous for Factor V Leiden mutation and prothrombin G20210A mutation

TABLE NOT AVAILABLE

Reference List
1. Vossen CY, Walker ID, Svensson P et al. Recurrence rate after a first venous thrombosis in patients with familial thrombophilia. Arterioscler Thromb Vasc Biol 2005; 25(9):1992–7.; 2. Palareti G, Legnani C, Cosmi B et al. Predictive value of D-dimer test for recurrent venous thromboembolism after anticoagulation withdrawal in subjects with a previous idiopathic event and in carriers of congenital thrombophilia. Circulation 2003; 108(3):313–8.; 3. Miles JS, Miletich JP, Goldhaber SZ, Hennekens CH, Ridker PM. G20210A mutation in the prothrombin gene and the risk of recurrent venous thromboembolism. J Am Coll Cardiol 2001; 37(1):215–8.; 4. Simioni P, Prandoni P, Lensing AW et al. Risk for subsequent venous thromboembolic complications in carriers of the prothrombin or the factor V gene mutation with a first episode of deep-vein thrombosis. Blood 2000; 96(10):3329–33.

Evidence Table 10 Results for probands heterozygous for prothrombin G20210A

TABLE NOT AVAILABLE

Reference List
1. Gonzalez-Porras JR, Garcia-Sanz R, Alberca I et al. Risk of recurrent venous thrombosis in patients with G20210A mutation in the prothrombin gene or factor V Leiden mutation. Blood Coagul Fibrinolysis 2006; 17(1):23–8.; 2. Wahlander K, Eriksson H, Lundstrom T et al. Risk of recurrent venous thromboembolism or bleeding in relation to thrombophilic risk factors in patients receiving ximelagatran or placebo for long-term secondary prevention of venous thromboembolism. Br J Haematol 2006; 133(1):68–77.; Notes: CORPORATE NAME: THRIVE III Investigators; 3. Mansilha A, Araujo F, Severo M, Sampaio SM, Toledo T, Albuquerque R. Genetic polymorphisms and risk of recurrent deep venous thrombosis in young people: prospective cohort study. Eur J Vasc Endovasc Surg 2005; 30(5):545–9.; 4. Palareti G, Legnani C, Cosmi B et al. Predictive value of D-dimer test for recurrent venous thromboembolism after anticoagulation withdrawal in subjects with a previous idiopathic event and in carriers of congenital thrombophilia. Circulation 2003; 108(3):313–8.; 5. Miles JS, Miletich JP, Goldhaber SZ, Hennekens CH, Ridker PM. G20210A mutation in the prothrombin gene and the risk of recurrent venous thromboembolism. J Am Coll Cardiol 2001; 37(1):215–8.; 6. Simioni P, Prandoni P, Lensing AW et al. Risk for subsequent venous thromboembolic complications in carriers of the prothrombin or the factor V gene mutation with a first episode of deep-vein thrombosis. Blood 2000; 96(10):3329–33.; 7. Lindmarker P, Schulman S, Sten-Linder M, Wiman B, Egberg N, Johnsson H. The risk of recurrent venous thromboembolism in carriers and non-carriers of the G1691A allele in the coagulation factor V gene and the G20210A allele in the prothrombin gene. DURAC Trial Study Group. Duration of Anticoagulation. Thromb Haemost 1999; 81(5):684–9.; 8. Prandoni P, Noventa F, Ghirarduzzi A et al. The risk of recurrent venous thromboembolism after discontinuing anticoagulation in patients with acute proximal deep vein thrombosis or pulmonary embolism. A prospective cohort study in 1,626 patients. Haematologica 2007; 92(2):199–205.; 9. Kearon C, Gent M, Hirsh J et al. A comparison of three months of anticoagulation with extended anticoagulation for a first episode of idiopathic venous thromboembolism. N Engl J Med 1999; 340(12):901–7.; 10. Kearon C, Julian JA, Kovacs MJ et al. Influence of thrombophilia on risk of recurrent venous thromboembolism while on warfarin: Results from a randomized trial. Blood 2008.

Evidence Table 11 TABLE NOT AVAILABLE

Reference List
1. Hron G, Eichinger S, Weltermann A et al. Family history for venous thromboembolism and the risk for recurrence. Am J Med 2006; 119(1):50–3.; 2. Santamaria MG, Agnelli G, Taliani MR et al. Thrombophilic abnormalities and recurrence of venous thromboembolism in patients treated with standardized anticoagulant treatment. Thromb Res 2005; 116(4):301–6.; 3. Baarslag HJ, Koopman MM, Hutten BA et al. Long-term follow-up of patients with suspected deep vein thrombosis of the upper extremity: survival, risk factors and post-thrombotic syndrome. Eur J Intern Med 2004; 15(8):503–7.; 4. Kyrle PA, Minar E, Bialonczyk C, Hirschl M, Weltermann A, Eichinger S. The risk of recurrent venous thromboembolism in men and women. N Engl J Med 2004; 350(25):2558–63.; 5. Baglin T, Luddington R, Brown K, Baglin C. Incidence of recurrent venous thromboembolism in relation to clinical and thrombophilic risk factors: prospective cohort study. Lancet 2003; 362(9383):523–6.; 6. Christiansen SC, Cannegieter SC, Koster T, Vandenbroucke JP, Rosendaal FR. Thrombophilia, clinical factors, and recurrent venous thrombotic events. JAMA 2005; 293(19):2352–61.; 7. Eichinger S, Minar E, Hirschl M et al. The risk of early recurrent venous thromboembolism after oral anticoagulant therapy in patients with the G20210A transition in the prothrombin gene. Thromb Haemost 1999; 81(1):14–7.

Evidence Table 12 Results for probands homozygous for prothrombin G20210A

TABLE NOT AVAILABLE

Reference List
1. Wahlander K, Eriksson H, Lundstrom T et al. Risk of recurrent venous thromboembolism or bleeding in relation to thrombophilic risk factors in patients receiving ximelagatran or placebo for long-term secondary prevention of venous thromboembolism. Br J Haematol 2006; 133(1):68–77.; Notes: CORPORATE NAME: THRIVE III Investigators; 2. Kearon C, Julian JA, Kovacs MJ et al. Influence of thrombophilia on risk of recurrent venous thromboembolism while on warfarin: Results from a randomized trial. Blood 2008.

Evidence Table 13 Quality of studies addressing Factor V Leiden and Prothrombin G20210A predicting events in family members

TABLE NOT AVAILABLE

Reference List
1. Samama MM, Simon D, Horellou MH, Trossaert M, Elalamy I, Conard J. Diagnosis and clinical characteristics of inherited activated protein C resistance. Haemostasis 1996; 26 Suppl 4:315–30.; 2. Middeldorp S, Henkens CM, Koopman MM et al. The incidence of venous thromboembolism in family members of patients with factor V Leiden mutation and venous thrombosis. Ann Intern Med 1998; 128(1):15–20.; 3. Le Cam-Duchez V, Gandrille S, Tregouet D et al. Influence of three potential genetic risk factors for thrombosis in 43 families carrying the factor V Arg 506 to Gln mutation. Br J Haematol 1999; 106(4):889–97.; 4. Simioni P, Sanson BJ, Prandoni P et al. Incidence of venous thromboembolism in families with inherited thrombophilia. Thromb Haemost 1999; 81(2):198–202.; 5. Simioni P, Prandoni P, Girolami A. Low rate of venous thromboembolism in asymptomatic relatives of probands with factor V Leiden mutation. Ann Intern Med 1999; 130(6):538.; 6. Lensen R, Rosendaal F, Vandenbroucke J, Bertina R. Factor V Leiden: the venous thrombotic risk in thrombophilic families. Br J Haematol 2000; 110(4):939–45.; 7. Martinelli I, Bucciarelli P, Margaglione M, De Stefano V, Castaman G, Mannucci PM. The risk of venous thromboembolism in family members with mutations in the genes of factor V or prothrombin or both. Br J Haematol 2000; 111(4):1223–9.; 8. Simioni P, Tormene D, Luni S, Caldato M, Girolami A. Clinical and laboratory expression of associated thrombophilic conditions (homozygous/heterozygous factor V Leiden mutation and heterozygous prothrombin variant 20210A) in an Italian family. Blood Coagul Fibrinolysis 2000; 11(4):379–84.; 9. Lensen R, Bertina RM, Vandenbroucke JP, Rosendaal FR. High factor VIII levels contribute to the thrombotic risk in families with factor V Leiden. Br J Haematol 2001; 114(2):380–6.; 10. Middeldorp S, Meinardi JR, Koopman MM et al. A prospective study of asymptomatic carriers of the factor V Leiden mutation to determine the incidence of venous thromboembolism. Ann Intern Med 2001; 135(5):322–7.; 11. Middeldorp S, Libourel EJ, Hamulyak K, Van der Meer J, Buller HR. The risk of pregnancy-related venous thromboembolism in women who are homozygous for factor V Leiden. Br J Haematol 2001; 113(2):553–5.; 12. Rintelen C, Pabinger I, Bettelheim P et al. Impact of the factor II: G20210A variant on the risk of venous thromboembolism in relatives from families with the factor V: R506Q mutation. Eur J Haematol 2001; 67(3):165–9.; 13. Meinardi JR, Middeldorp S, de Kam PJ et al. The incidence of recurrent venous thromboembolism in carriers of factor V Leiden is related to concomitant thrombophilic disorders. Br J Haematol 2002; 116(3):625–31.; 14. Simioni P, Tormene D, Prandoni P et al. Incidence of venous thromboembolism in asymptomatic family members who are carriers of factor V Leiden: a prospective cohort study. Blood 2002; 99(6):1938–42.; 15. Vossen CY, Conard J, Fontcuberta J et al. Familial thrombophilia and lifetime risk of venous thrombosis. J Thromb Haemost 2004; 2(9):1526–32.; 16. Vossen CY, Conard J, Fontcuberta J et al. Risk of a first venous thrombotic event in carriers of a familial thrombophilic defect. The European Prospective Cohort on Thrombophilia (EPCOT). J Thromb Haemost 2005; 3(3):459–64.; 17. Couturaud F, Kearon C, Leroyer C et al. Incidence of venous thromboembolism in first-degree relatives of patients with venous thromboembolism who have factor V Leiden. Thromb Haemost 2006; 96(6):744–9.; Notes: CORPORATE NAME: Groupe d'Etude de la Thrombose de Bretagne Occidentale (G.E.T.B.O); 18. Castaman G, Tosetto A, Cappellari A, Ruggeri M, Rodeghiero F. The A20210 allele in the prothrombin gene enhances the risk of venous thrombosis in carriers of inherited protein S deficiency. Blood Coagul Fibrinolysis 2000; 11(4):321–6.; 19. Martinelli I, Legnani C, Bucciarelli P, Grandone E, De Stefano V, Mannucci PM. Risk of pregnancy-related venous thrombosis in carriers of severe inherited thrombophilia. Thromb Haemost 2001; 86(3):800–3.; 20. Tormene D, Simioni P, Prandoni P et al. Factor V Leiden mutation and the risk of venous thromboembolism in pregnant women. Haematologica 2001; 86(12):1305–9.; 21. Tormene D, De Stefano V, Grandone E et al. The G20210A prothrombin variant and the risk of venous thromboembolism or fetal loss in pregnant women: a family study. J Thromb Haemost 2007; 5(11):2193–6.; 22. Martinelli I, Battaglioli T, De Stefano V et al. The risk of first venous thromboembolism during pregnancy and puerperium in double heterozygotes for factor V Leiden and prothrombin G20210A. J Thromb Haemost 2008; 6(3):494–8.; Notes: CORPORATE NAME: GIT (Gruppo Italiano Trombofilia)

Evidence Table 14 FVL predicting events in family members, study characteristics

TABLE NOT AVAILABLE

Reference List
1. Samama MM, Simon D, Horellou MH, Trossaert M, Elalamy I, Conard J. Diagnosis and clinical characteristics of inherited activated protein C resistance. Haemostasis 1996; 26 Suppl 4:315–30.; 2. Middeldorp S, Henkens CM, Koopman MM et al. The incidence of venous thromboembolism in family members of patients with factor V Leiden mutation and venous thrombosis. Ann Intern Med 1998; 128(1):15–20.; 3. Le Cam-Duchez V, Gandrille S, Tregouet D et al. Influence of three potential genetic risk factors for thrombosis in 43 families carrying the factor V Arg 506 to Gln mutation. Br J Haematol 1999; 106(4):889–97.; 4. Simioni P, Sanson BJ, Prandoni P et al. Incidence of venous thromboembolism in families with inherited thrombophilia. Thromb Haemost 1999; 81(2):198–202.; 5. Simioni P, Prandoni P, Girolami A. Low rate of venous thromboembolism in asymptomatic relatives of probands with factor V Leiden mutation. Ann Intern Med 1999; 130(6):538.; 6. Lensen R, Rosendaal F, Vandenbroucke J, Bertina R. Factor V Leiden: the venous thrombotic risk in thrombophilic families. Br J Haematol 2000; 110(4):939–45.; 7. Martinelli I, Bucciarelli P, Margaglione M, De Stefano V, Castaman G, Mannucci PM. The risk of venous thromboembolism in family members with mutations in the genes of factor V or prothrombin or both. Br J Haematol 2000; 111(4):1223–9.; 8. Simioni P, Tormene D, Luni S, Caldato M, Girolami A. Clinical and laboratory expression of associated thrombophilic conditions (homozygous/heterozygous factor V Leiden mutation and heterozygous prothrombin variant 20210A) in an Italian family. Blood Coagul Fibrinolysis 2000; 11(4):379–84.; 9. Lensen R, Bertina RM, Vandenbroucke JP, Rosendaal FR. High factor VIII levels contribute to the thrombotic risk in families with factor V Leiden. Br J Haematol 2001; 114(2):380–6.; 10. Middeldorp S, Meinardi JR, Koopman MM et al. A prospective study of asymptomatic carriers of the factor V Leiden mutation to determine the incidence of venous thromboembolism. Ann Intern Med 2001; 135(5):322–7.; 11. Rintelen C, Pabinger I, Bettelheim P et al. Impact of the factor II: G20210A variant on the risk of venous thromboembolism in relatives from families with the factor V: R506Q mutation. Eur J Haematol 2001; 67(3):165–9.; 12. Meinardi JR, Middeldorp S, de Kam PJ et al. The incidence of recurrent venous thromboembolism in carriers of factor V Leiden is related to concomitant thrombophilic disorders. Br J Haematol 2002; 116(3):625–31.; 13. Simioni P, Tormene D, Prandoni P et al. Incidence of venous thromboembolism in asymptomatic family members who are carriers of factor V Leiden: a prospective cohort study. Blood 2002; 99(6):1938–42.; 14. Vossen CY, Conard J, Fontcuberta J et al. Familial thrombophilia and lifetime risk of venous thrombosis. J Thromb Haemost 2004; 2(9):1526–32.; 15. Vossen CY, Conard J, Fontcuberta J et al. Risk of a first venous thrombotic event in carriers of a familial thrombophilic defect. The European Prospective Cohort on Thrombophilia (EPCOT). J Thromb Haemost 2005; 3(3):459–64.; 16. Couturaud F, Kearon C, Leroyer C et al. Incidence of venous thromboembolism in first-degree relatives of patients with venous thromboembolism who have factor V Leiden. Thromb Haemost 2006; 96(6):744–9.; Notes: CORPORATE NAME: Groupe d’Etude de la Thrombose de Bretagne Occidentale (G.E.T.B.O)

Evidence Table 15 Results of studies of family members with Factor V Leiden

TABLE NOT AVAILABLE

Reference List
1. Samama MM, Simon D, Horellou MH, Trossaert M, Elalamy I, Conard J. Diagnosis and clinical characteristics of inherited activated protein C resistance. Haemostasis 1996; 26 Suppl 4:315–30.; 2. Middeldorp S, Henkens CM, Koopman MM et al. The incidence of venous thromboembolism in family members of patients with factor V Leiden mutation and venous thrombosis. Ann Intern Med 1998; 128(1):15–20.; 3. Le Cam-Duchez V, Gandrille S, Tregouet D et al. Influence of three potential genetic risk factors for thrombosis in 43 families carrying the factor V Arg 506 to Gln mutation. Br J Haematol 1999; 106(4):889–97.; 4. Simioni P, Sanson BJ, Prandoni P et al. Incidence of venous thromboembolism in families with inherited thrombophilia. Thromb Haemost 1999; 81(2):198–202.; 5. Simioni P, Prandoni P, Girolami A. Low rate of venous thromboembolism in asymptomatic relatives of probands with factor V Leiden mutation. Ann Intern Med 1999; 130(6):538.; 6. Lensen R, Rosendaal F, Vandenbroucke J, Bertina R. Factor V Leiden: the venous thrombotic risk in thrombophilic families. Br J Haematol 2000; 110(4):939–45.; 7. Martinelli I, Bucciarelli P, Margaglione M, De Stefano V, Castaman G, Mannucci PM. The risk of venous thromboembolism in family members with mutations in the genes of factor V or prothrombin or both. Br J Haematol 2000; 111(4):1223–9.; 8. Simioni P, Tormene D, Luni S, Caldato M, Girolami A. Clinical and laboratory expression of associated thrombophilic conditions (homozygous/heterozygous factor V Leiden mutation and heterozygous prothrombin variant 20210A) in an Italian family. Blood Coagul Fibrinolysis 2000; 11(4):379–84.; 9. Lensen R, Bertina RM, Vandenbroucke JP, Rosendaal FR. High factor VIII levels contribute to the thrombotic risk in families with factor V Leiden. Br J Haematol 2001; 114(2):380–6.; 10. Middeldorp S, Meinardi JR, Koopman MM et al. A prospective study of asymptomatic carriers of the factor V Leiden mutation to determine the incidence of venous thromboembolism. Ann Intern Med 2001; 135(5):322–7.; 11. Rintelen C, Pabinger I, Bettelheim P et al. Impact of the factor II: G20210A variant on the risk of venous thromboembolism in relatives from families with the factor V: R506Q mutation. Eur J Haematol 2001; 67(3):165–9.; 12. Meinardi JR, Middeldorp S, de Kam PJ et al. The incidence of recurrent venous thromboembolism in carriers of factor V Leiden is related to concomitant thrombophilic disorders. Br J Haematol 2002; 116(3):625–31.; 13. Simioni P, Tormene D, Prandoni P et al. Incidence of venous thromboembolism in asymptomatic family members who are carriers of factor V Leiden: a prospective cohort study. Blood 2002; 99(6):1938–42.; 14. Vossen CY, Conard J, Fontcuberta J et al. Familial thrombophilia and lifetime risk of venous thrombosis. J Thromb Haemost 2004; 2(9):1526–32.; 15. Vossen CY, Conard J, Fontcuberta J et al. Risk of a first venous thrombotic event in carriers of a familial thrombophilic defect. The European Prospective Cohort on Thrombophilia (EPCOT). J Thromb Haemost 2005; 3(3):459–64.; 16. Couturaud F, Kearon C, Leroyer C et al. Incidence of venous thromboembolism in first-degree relatives of patients with venous thromboembolism who have factor V Leiden. Thromb Haemost 2006; 96(6):744–9.; Notes: CORPORATE NAME: Groupe d’Etude de la Thrombose de Bretagne Occidentale (G.E.T.B.O)

Evidence Table 16 Characteristics of studies of prothrombin G20210A in family members

TABLE NOT AVAILABLE

Reference List
1. Castaman G, Tosetto A, Cappellari A, Ruggeri M, Rodeghiero F. The A20210 allele in the prothrombin gene enhances the risk of venous thrombosis in carriers of inherited protein S deficiency. Blood Coagul Fibrinolysis 2000; 11(4):321–6.; 2. Martinelli I, Bucciarelli P, Margaglione M, De Stefano V, Castaman G, Mannucci PM. The risk of venous thromboembolism in family members with mutations in the genes of factor V or prothrombin or both. Br J Haematol 2000; 111(4):1223–9.; 3. Simioni P, Tormene D, Luni S, Caldato M, Girolami A. Clinical and laboratory expression of associated thrombophilic conditions (homozygous/heterozygous factor V Leiden mutation and heterozygous prothrombin variant 20210A) in an Italian family. Blood Coagul Fibrinolysis 2000; 11(4):379–84.; 4. Rintelen C, Pabinger I, Bettelheim P et al. Impact of the factor II: G20210A variant on the risk of venous thromboembolism in relatives from families with the factor V: R506Q mutation. Eur J Haematol 2001; 67(3):165–9.; 5. Couturaud F, Kearon C, Leroyer C et al. Incidence of venous thromboembolism in first-degree relatives of patients with venous thromboembolism who have factor V Leiden. Thromb Haemost 2006; 96(6):744–9.; Notes: CORPORATE NAME: Groupe d’Etude de la Thrombose de Bretagne Occidentale (G.E.T.B.O)

Evidence Table 17 Results of studies on prothrombin G20210A predicting events in family members

TABLE NOT AVAILABLE

Reference List
1. Castaman G, Tosetto A, Cappellari A, Ruggeri M, Rodeghiero F. The A20210 allele in the prothrombin gene enhances the risk of venous thrombosis in carriers of inherited protein S deficiency. Blood Coagul Fibrinolysis 2000; 11(4):321–6.; 2. Martinelli I, Bucciarelli P, Margaglione M, De Stefano V, Castaman G, Mannucci PM. The risk of venous thromboembolism in family members with mutations in the genes of factor V or prothrombin or both. Br J Haematol 2000; 111(4):1223–9.; 3. Simioni P, Tormene D, Luni S, Caldato M, Girolami A. Clinical and laboratory expression of associated thrombophilic conditions (homozygous/heterozygous factor V Leiden mutation and heterozygous prothrombin variant 20210A) in an Italian family. Blood Coagul Fibrinolysis 2000; 11(4):379–84.; 4. Rintelen C, Pabinger I, Bettelheim P et al. Impact of the factor II: G20210A variant on the risk of venous thromboembolism in relatives from families with the factor V: R506Q mutation. Eur J Haematol 2001; 67(3):165–9.; 5. Couturaud F, Kearon C, Leroyer C et al. Incidence of venous thromboembolism in first-degree relatives of patients with venous thromboembolism who have factor V Leiden. Thromb Haemost 2006; 96(6):744–9.; Notes: CORPORATE NAME: Groupe d’Etude de la Thrombose de Bretagne Occidentale (G.E.T.B.O)

Evidence Table 18 Characteristics of studies of Factor V Leiden and prothrombin G20210A in pregnant family members

TABLE NOT AVAILABLE

Reference List
1. Martinelli I, Legnani C, Bucciarelli P, Grandone E, De Stefano V, Mannucci PM. Risk of pregnancy-related venous thrombosis in carriers of severe inherited thrombophilia. Thromb Haemost 2001; 86(3):800–3.; 2. Middeldorp S, Libourel EJ, Hamulyak K, Van der Meer J, Buller HR. The risk of pregnancy-related venous thromboembolism in women who are homozygous for factor V Leiden. Br J Haematol 2001; 113(2):553–5.; 3. Tormene D, Simioni P, Prandoni P et al. Factor V Leiden mutation and the risk of venous thromboembolism in pregnant women. Haematologica 2001; 86(12):1305–9.; 4. Couturaud F, Kearon C, Leroyer C et al. Incidence of venous thromboembolism in first-degree relatives of patients with venous thromboembolism who have factor V Leiden. Thromb Haemost 2006; 96(6):744–9.; Notes: CORPORATE NAME: Groupe d’Etude de la Thrombose de Bretagne Occidentale (G.E.T.B.O); 5. Tormene D, De Stefano V, Grandone E et al. The G20210A prothrombin variant and the risk of venous thromboembolism or fetal loss in pregnant women: a family study. J Thromb Haemost 2007; 5(11):2193–6.; 6. Martinelli I, Battaglioli T, De Stefano V et al. The risk of first venous thromboembolism during pregnancy and puerperium in double heterozygotes for factor V Leiden and prothrombin G20210A. J Thromb Haemost 2008; 6(3):494–8.; Notes: CORPORATE NAME: GIT (Gruppo Italiano Trombofilia)

Evidence Table 19 Results of studies of Factor V Leiden and prothrombin G20210A in pregnant family members

TABLE NOT AVAILABLE

Reference List
1. Martinelli I, Legnani C, Bucciarelli P, Grandone E, De Stefano V, Mannucci PM. Risk of pregnancy-related venous thrombosis in carriers of severe inherited thrombophilia. Thromb Haemost 2001; 86(3):800–3.; 2. Middeldorp S, Libourel EJ, Hamulyak K, Van der Meer J, Buller HR. The risk of pregnancy-related venous thromboembolism in women who are homozygous for factor V Leiden. Br J Haematol 2001; 113(2):553–5.; 3. Tormene D, Simioni P, Prandoni P et al. Factor V Leiden mutation and the risk of venous thromboembolism in pregnant women. Haematologica 2001; 86(12):1305–9.; 4. Couturaud F, Kearon C, Leroyer C et al. Incidence of venous thromboembolism in first-degree relatives of patients with venous thromboembolism who have factor V Leiden. Thromb Haemost 2006; 96(6):744–9.; Notes: CORPORATE NAME: Groupe d’Etude de la Thrombose de Bretagne Occidentale (G.E.T.B.O); 5. Tormene D, De Stefano V, Grandone E et al. The G20210A prothrombin variant and the risk of venous thromboembolism or fetal loss in pregnant women: a family study. J Thromb Haemost 2007; 5(11):2193–6.; 6. Martinelli I, Battaglioli T, De Stefano V et al. The risk of first venous thromboembolism during pregnancy and puerperium in double heterozygotes for factor V Leiden and prothrombin G20210A. J Thromb Haemost 2008; 6(3):494–8.; Notes: CORPORATE NAME: GIT (Gruppo Italiano Trombofilia)

Evidence Table 20 Quality of studies using survey designs included for effect of testing on clinicians’ management or effect of testing and results on other outcomes

TABLE NOT AVAILABLE

Reference List
1. Heshka J, Palleschi C, Wilson B et al. Cognitive and Behavioural Effects of Genetic Testing for Thrombophilia. J Genet Couns 2008.; 2. Kaptein AA, van Korlaar IM, Cameron LD, Vossen CY, van der Meer FJ, Rosendaal FR. Using the common-sense model to predict risk perception and disease-related worry in individuals at increased risk for venous thrombosis. Health Psychol 2007; 26(6):807–12.; 3. Rodger MA, Carrier M, Keely E et al. The management of thrombophilia during pregnancy: a Canadian survey. J Obstet Gynaecol Can 2002; 24(12):946–52.; 4. Vossen CY, Walker ID, Svensson P et al. Recurrence rate after a first venous thrombosis in patients with familial thrombophilia. Arterioscler Thromb Vasc Biol 2005; 25(9):1992–7.; 5. Wahlander K, Eriksson H, Lundstrom T et al. Risk of recurrent venous thromboembolism or bleeding in relation to thrombophilic risk factors in patients receiving ximelagatran or placebo for long-term secondary prevention of venous thromboembolism. Br J Haematol 2006; 133(1):68–77.; Notes: CORPORATE NAME: THRIVE III Investigators; 6. Kearon C, Julian JA, Kovacs MJ et al. Influence of thrombophilia on risk of recurrent venous thromboembolism while on warfarin: Results from a randomized trial. Blood 2008.; 7. Ridker PM, Goldhaber SZ, Danielson E et al. Long-term, low-intensity warfarin therapy for the prevention of recurrent venous thromboembolism. N Engl J Med 2003; 348(15):1425–34.; Notes: CORPORATE NAME: PREVENT Investigators; 8. Saukko PM, Ellard S, Richards SH, Shepherd MH, Campbell JL. Patients’ understanding of genetic susceptibility testing in mainstream medicine: qualitative study on thrombophilia. BMC Health Serv Res 2007; 7:82.; 9. Saukko PM, Richards SH, Shepherd MH, Campbell JL. Are genetic tests exceptional? Lessons from a qualitative study on thrombophilia. Soc Sci Med 2006; 63(7):1947–59.; 10. Bank I, Scavenius MP, Buller HR, Middeldorp S. Social aspects of genetic testing for factor V Leiden mutation in healthy individuals and their importance for daily practice. Thromb Res 2004; 113(1):7–12.

Evidence Table 21 Study characteristics for studies on effect of testing on clinicians’ management and the effect of testing and results on other outcomes

TABLE NOT AVAILABLE

Reference List
1. Rodger MA, Carrier M, Keely E et al. The management of thrombophilia during pregnancy: a Canadian survey. J Obstet Gynaecol Can 2002; 24(12):946–52.; 2. Bank I, Scavenius MP, Buller HR, Middeldorp S. Social aspects of genetic testing for factor V Leiden mutation in healthy individuals and their importance for daily practice. Thromb Res 2004; 113(1):7–12.; 3. Kaptein AA, van Korlaar IM, Cameron LD, Vossen CY, van der Meer FJ, Rosendaal FR. Using the common-sense model to predict risk perception and disease-related worry in individuals at increased risk for venous thrombosis. Health Psychol 2007; 26(6):807–12.; 4. Saukko PM, Ellard S, Richards SH, Shepherd MH, Campbell JL. Patients’ understanding of genetic susceptibility testing in mainstream medicine: qualitative study on thrombophilia. BMC Health Serv Res 2007; 7:82.; 5. Saukko PM, Richards SH, Shepherd MH, Campbell JL. Are genetic tests exceptional? Lessons from a qualitative study on thrombophilia. Soc Sci Med 2006; 63(7):1947–59.; 6. Heshka J, Palleschi C, Wilson B et al. Cognitive and Behavioural Effects of Genetic Testing for Thrombophilia. J Genet Couns 2008.

Evidence Table 22 Study characteristics for studies on the effect of testing on management

TABLE NOT AVAILABLE

Reference List
1. Vossen CY, Walker ID, Svensson P et al. Recurrence rate after a first venous thrombosis in patients with familial thrombophilia. Arterioscler Thromb Vasc Biol 2005; 25(9):1992–7.; 2. Wahlander K, Eriksson H, Lundstrom T et al. Risk of recurrent venous thromboembolism or bleeding in relation to thrombophilic risk factors in patients receiving ximelagatran or placebo for long-term secondary prevention of venous thromboembolism. Br J Haematol 2006; 133(1):68–77.; Notes: CORPORATE NAME: THRIVE III Investigators; 3. Kearon C, Julian JA, Kovacs MJ et al. Influence of thrombophilia on risk of recurrent venous thromboembolism while on warfarin: Results from a randomized trial. Blood 2008.; 4. Ridker PM, Goldhaber SZ, Danielson E et al. Long-term, low-intensity warfarin therapy for the prevention of recurrent venous thromboembolism. N Engl J Med 2003; 348(15):1425–34.; Notes: CORPORATE NAME: PREVENT Investigators

Evidence Table 23 Population characteristics for studies addressing other effects of testing

TABLE NOT AVAILABLE

Reference List
1. Vossen CY, Walker ID, Svensson P et al. Recurrence rate after a first venous thrombosis in patients with familial thrombophilia. Arterioscler Thromb Vasc Biol 2005; 25(9):1992–7.; 2. Wahlander K, Eriksson H, Lundstrom T et al. Risk of recurrent venous thromboembolism or bleeding in relation to thrombophilic risk factors in patients receiving ximelagatran or placebo for long-term secondary prevention of venous thromboembolism. Br J Haematol 2006; 133(1):68–77.; Notes: CORPORATE NAME: THRIVE III Investigators; 3. Kearon C, Julian JA, Kovacs MJ et al. Influence of thrombophilia on risk of recurrent venous thromboembolism while on warfarin: Results from a randomized trial. Blood 2008.; 4. Ridker PM, Goldhaber SZ, Danielson E et al. Long-term, low-intensity warfarin therapy for the prevention of recurrent venous thromboembolism. N Engl J Med 2003; 348(15):1425–34.; Notes: CORPORATE NAME: PREVENT Investigators

Evidence Table 24 Results for articles addressing the effects of testing on VTE outcomes

TABLE NOT AVAILABLE

Reference List
1. Vossen CY, Walker ID, Svensson P et al. Recurrence rate after a first venous thrombosis in patients with familial thrombophilia. Arterioscler Thromb Vasc Biol 2005; 25(9):1992–7.; 2. Wahlander K, Eriksson H, Lundstrom T et al. Risk of recurrent venous thromboembolism or bleeding in relation to thrombophilic risk factors in patients receiving ximelagatran or placebo for long-term secondary prevention of venous thromboembolism. Br J Haematol 2006; 133(1):68–77.; Notes: CORPORATE NAME: THRIVE III Investigators; 3. Kearon C, Julian JA, Kovacs MJ et al. Influence of thrombophilia on risk of recurrent venous thromboembolism while on warfarin: Results from a randomized trial. Blood 2008.; 4. Ridker PM, Goldhaber SZ, Danielson E et al. Long-term, low-intensity warfarin therapy for the prevention of recurrent venous thromboembolism. N Engl J Med 2003; 348(15):1425–34.; Notes: CORPORATE NAME: PREVENT Investigators

Evidence Table 25 Description of Studies Evaluating the Cost-Effectiveness of Testing for Factor V Leiden or Prothrombin G20210A Mutation

TABLE NOT AVAILABLE

Reference List
1. Sarasin FP, Bounameaux H. Decision analysis model of prolonged oral anticoagulant treatment in factor V Leiden carriers with first episode of deep vein thrombosis. BMJ 1998; 316(7125):95–9.; 2. Marchetti M, Quaglini S, Barosi G. Cost-effectiveness of screening and extended anticoagulation for carriers of both factor V Leiden and prothrombin G20210A. QJM 2001; 94(7):365–72.; 3. Marchetti M, Pistorio A, Barosi G. Extended anticoagulation for prevention of recurrent venous thromboembolism in carriers of factor V Leiden--cost-effectiveness analysis. Thromb Haemost 2000; 84(5):752–7.; 4. Eckman MH, Singh SK, Erban JK, Kao G. Testing for factor V Leiden in patients with pulmonary or venous thromboembolism: a cost-effectiveness analysis. Med Decis Making 2002; 22(2):108–24.; 5. Clark P, Twaddle S, Walker ID, Scott L, Greer IA. Cost-effectiveness of screening for the factor V Leiden mutation in pregnant women. Lancet 2002; 359(9321):1919–20.; 6. Auerbach AD, Sanders GD, Hambleton J. Cost-effectiveness of testing for hypercoagulability and effects on treatment strategies in patients with deep vein thrombosis. Am J Med 2004; 116(12):816–28.; 7. Wu O, Robertson L, Twaddle S et al. Screening for thrombophilia in high-risk situations: systematic review and cost-effectiveness analysis. The Thrombosis: Risk and Economic Assessment of Thrombophilia Screening (TREATS) study. Health Technol Assess 2006; 10(11):1–110.

Evidence Table 26 Quality Assessment of the Studies Evaluating the Cost-Effectiveness of Testing for Factor V Leiden or Prothrombin G20210A Mutation

TABLE NOT AVAILABLE

Reference List
1. Sarasin FP, Bounameaux H. Decision analysis model of prolonged oral anticoagulant treatment in factor V Leiden carriers with first episode of deep vein thrombosis. BMJ 1998; 316(7125):95–9.; 2. Marchetti M, Quaglini S, Barosi G. Cost-effectiveness of screening and extended anticoagulation for carriers of both factor V Leiden and prothrombin G20210A. QJM 2001; 94( 7):365–72.; 3. Marchetti M, Pistorio A, Barosi G. Extended anticoagulation for prevention of recurrent venous thromboembolism in carriers of factor V Leiden--cost-effectiveness analysis. Thromb Haemost 2000; 84(5):752–7.; 4. Eckman MH, Singh SK, Erban JK, Kao G. Testing for factor V Leiden in patients with pulmonary or venous thromboembolism: a cost-effectiveness analysis. Med Decis Making 2002; 22(2):108–24.; 5. Clark P, Twaddle S, Walker ID, Scott L, Greer IA. Cost-effectiveness of screening for the factor V Leiden mutation in pregnant women. Lancet 2002; 359(9321):1919–20.; 6. Auerbach AD, Sanders GD, Hambleton J. Cost-effectiveness of testing for hypercoagulability and effects on treatment strategies in patients with deep vein thrombosis. Am J Med 2004; 116(12):816–28.; 7. Wu O, Robertson L, Twaddle S et al. Screening for thrombophilia in high-risk situations: systematic review and cost-effectiveness analysis. The Thrombosis: Risk and Economic Assessment of Thrombophilia Screening (TREATS) study. Health Technol Assess 2006; 10(11):1–110.

Evidence Table 27 Applicability of the Studies Evaluating the Cost-Effectiveness of Testing for Factor V Leiden or Prothrombin G20210A Mutation to Research Question

TABLE NOT AVAILABLE

Reference List
1. Sarasin FP, Bounameaux H. Decision analysis model of prolonged oral anticoagulant treatment in factor V Leiden carriers with first episode of deep vein thrombosis. BMJ 1998; 316(7125):95–9.; 2. Marchetti M, Quaglini S, Barosi G. Cost-effectiveness of screening and extended anticoagulation for carriers of both factor V Leiden and prothrombin G20210A. QJM 2001; 94(7):365–72.; 3. Marchetti M, Pistorio A, Barosi G. Extended anticoagulation for prevention of recurrent venous thromboembolism in carriers of factor V Leiden--cost-effectiveness analysis. Thromb Haemost 2000; 84(5):752–7.; 4. Eckman MH, Singh SK, Erban JK, Kao G. Testing for factor V Leiden in patients with pulmonary or venous thromboembolism: a cost-effectiveness analysis. Med Decis Making 2002; 22(2):108–24.; 5. Clark P, Twaddle S, Walker ID, Scott L, Greer IA. Cost-effectiveness of screening for the factor V Leiden mutation in pregnant women. Lancet 2002; 359(9321):1919–20.; 6. Auerbach AD, Sanders GD, Hambleton J. Cost-effectiveness of testing for hypercoagulability and effects on treatment strategies in patients with deep vein thrombosis. Am J Med 2004; 116(12):816–28.; 7. Wu O, Robertson L, Twaddle S et al. Screening for thrombophilia in high-risk situations: systematic review and cost-effectiveness analysis. The Thrombosis: Risk and Economic Assessment of Thrombophilia Screening (TREATS) study. Health Technol Assess 2006; 10(11):1–110.