# Reviewer Comments

Excluded by AHRQ because of confidentiality.