# List of Excluded Articles

Medical devices; hematology and pathology devices; classification of the Factor V Leiden DNA mutation detection systems devices. Final rule. Fed Regist 2004;69(51):12271–3

Other reason

Investigation and management of heritable thrombophilia. Br J Haematol 2001;114(3):512–28

No original data

Comparison of thrombotic risk between 85 homozygotes and 481 heterozygotes carriers of the factor V Leiden mutation: retrospective analysis from the Procare Study. Blood Coagul Fibrinolysis 2000;11(6):511–8

Doesn't address study question

Adkins K K, Strom D A, Jacobson T E et al. Utilizing genomic DNA purified from clotted blood samples for single nucleotide polymorphism genotyping. Arch Pathol Lab Med 2002;126(3):266–70

Evaluates only DNA extraction methods

Agnelli G. Long-term low-dose warfarin use is effective in the prevention of recurrent venous thromboembolism: No. J. Thromb. Haemost. 2004;2(7):1038–1040

No original data

Aliev M A, Mierbekov E M, Sviatova G S et al. [Venous thromboembolic events in surgery: a role of genetic disorders]. Anesteziol Reanimatol 2008;(1):71–3

Non-English article

Altes A, Souto J C, Mateo J et al. Activated protein C resistance assay when applied in the general population. Am J Obstet Gynecol 97;176(2):358–9

Published before 2000

Amberger N, Masuhr F, Valdueza J M et al. A negative personal and family history for venous thrombotic events is not sufficient to exclude thrombophilia in patients with cerebral venous thrombosis. Eur J Neurol 2004;11(8):555–8

Does not report results separately for FV Leiden and/or PT 20210A.

Andersson H C, Krousel-Wood M A, Jackson K E et al. Medical genetic test reporting for cystic fibrosis (deltaF508) and factor V Leiden in North American laboratories. Genet Med 2002;4(5):324–7

Doesn't address study question

Angelini A, Di Febbo C, Baccante G et al. Identification of three genetic risk factors for venous thrombosis using a multiplex allele-specific PCR assay: comparison of conventional and new alternative methods for the preparation of DNA from clinical samples. J Thromb Thrombolysis 2003;16(3):189–93

Evaluates only DNA extraction methods

Angelini A, Di Febbo C, Rullo A et al. New method for the extraction of DNA from white blood cells for the detection of common genetic variants associated with thrombophilia. Pathophysiol Haemost Thromb 2002;32(4):180–3

Evaluates only DNA extraction methods

Arruda V R, von Zuben P M, Annichino-Bizzachi J M et al. Rapid detection of factor V Leiden (FVQ506) by non-radioactive single strand conformation polymorphism (SSCP). Sangre (Barc) 96;41(5):379–81

Published before 2000

Aslanidis C, Nauck M, Schmitz G. High-speed prothrombin G-->A 20210 and methylenetetrahydrofolate reductase C-->T 677 mutation detection using real-time fluorescence PCR and melting curves. Biotechniques 99;27(2):234–6, 238

Published before 2000

Aznar J, Vaya A, Estelles A et al. Risk of venous thrombosis in carriers of the prothrombin G20210A variant and factor V Leiden and their interaction with oral contraceptives. Haematologica 2000;85(12):1271–6

Case-control or retrospective cohort of probands

Baglin C, Brown K, Luddington R et al. Risk of recurrent venous thromboembolism in patients with the factor V Leiden (FVR506Q) mutation: effect of warfarin and prediction by precipitating factors. East Anglian Thrombophilia Study Group. Br J Haematol 98;100(4):764–8

Other reason

Bank I, Libourel E J, Middeldorp S et al. Prothrombin 20210A mutation: a mild risk factor for venous thromboembolism but not for arterial thrombotic disease and pregnancy-related complications in a family study. Arch Intern Med 2004;164(17):1932–7

Other reason

Bathelier C, Champenois T, Lucotte G. ARMS test for diagnosis of factor V Leiden mutation and allele frequencies in France. Mol Cell Probes 98;12(2):121–3

Published before 2000

Beauchamp N J, Daly M E, Cooper P C et al. Rapid two-stage PCR for detecting factor V G1691A mutation. Lancet 94;344(8923):694–5

Published before 2000

Behn M, Schuermann M. Simple and reliable factor V genotyping by PNA-mediated PCR clamping. Thromb Haemost 98;79(4):773–7

Published before 2000

Bennett C D, Campbell M N, Cook C J et al. The LightTyper: high-throughput genotyping using fluorescent melting curve analysis. Biotechniques 2003;34(6):1288–92, 1294–5

Other reason

Benson J M, Ellingsen D, Renshaw M A et al. Multiplex analysis of mutations in four genes using fluorescence scanning technology. Thromb Res 99;96(1):57–64

Published before 2000

Benson J M, Phillips D J, Holloway B P et al. Oligonucleotide ligation assay for detection of the factor V mutation (Arg506-->Gln) causing protein C resistance. Thromb Res 96;83(1):87–96

Published before 2000

Bertina R M. Molecular risk factors for thrombosis. Thromb Haemost 99;82(2):601–9

No original data

Biswas A, Bajaj J, Ranjan R et al. Factor V Leiden: Is it the chief contributor to activated protein C resistance in Asian-Indian patients with deep vein thrombosis?. Clin Chim Acta 2008;392(1–2):21–4

Doesn't address study question

Blasczyk R, Ritter M, Thiede C et al. Simple and rapid detection of factor V Leiden by allele-specific PCR amplification. Thromb Haemost 96;75(5):757–9

Published before 2000

Blasczyk R, Wehling J, Ritter M et al. Allele-specific PCR amplification of factor V Leiden to identify patients at risk for thromboembolism. Beitr Infusionsther Transfusionsmed 97;34236–41

Published before 2000

Boda Z, Laszlo P, Rejto L et al. Low molecular weight heparin as thromboprophylaxis in familial thrombophilia during the whole period of pregnancy. Thromb Haemost 96;76(1):128

Doesn't address study question

Bokarewa M I, Bremme K, Blomback M. Arg506-Gln mutation in factor V and risk of thrombosis during pregnancy. Br J Haematol 96;92(2):473–8

Other reason

Bokarewa M I, Falk G, Sten-Linder M et al. Thrombotic risk factors and oral contraception. J Lab Clin Med 95;126(3):294–8

Does not report results separately for FV Leiden and/or PT 20210A

Bounameaux H. Factor V Leiden paradox: risk of deep-vein thrombosis but not of pulmonary embolism. Lancet 2000;356(9225):182–3

Doesn't address study question

Bowen D J, Bowley S, John M et al. Factor V Leiden (G1691A), the prothrombin 3′-untranslated region variant (G20210A) and thermolabile methylenetetrahydrofolate reductase (C677T): a single genetic test genotypes all three loci--determination of frequencies in the S. Wales population of the UK. Thromb Haemost 98;79(5):949–54

Published before 2000

Bowen D J, Standen G R, Granville S et al. Genetic diagnosis of factor V Leiden using heteroduplex technology. Thromb Haemost 97;77(1):119–22

Published before 2000

Brenner B, Zivelin A, Lanir N et al. Venous thromboembolism associated with double heterozygosity for R506Q mutation of factor V and for T298M mutation of protein C in a large family of a previously described homozygous protein C-deficient newborn with massive thrombosis. Blood 96;88(3):877–80

Other reason

Brouwer J L, Bijl M, Veeger N J et al. The contribution of inherited and acquired thrombophilic defects, alone or combined with antiphospholipid antibodies, to venous and arterial thromboembolism in patients with systemic lupus erythematosus. Blood 2004;104(1):143–8

Does not report results separately for FV Leiden and/or PT 20210A

Buller H R, Davidson B L, Decousus H et al. Fondaparinux or enoxaparin for the initial treatment of symptomatic deep venous thrombosis: a randomized trial. Ann Intern Med 2004;140(11):867–73

Doesn't address study question

Buller H R, Davidson B L, Decousus H et al. Subcutaneous fondaparinux versus intravenous unfractionated heparin in the initial treatment of pulmonary embolism. N Engl J Med 2003;349(18):1695–702

Doesn't address study question

Caprini J A, Goldshteyn S, Glase C J et al. Thrombophilia testing in patients with venous thrombosis. Eur J Vasc Endovasc Surg 2005;30(5):550–5

Evaluates less than 10 probands or 10 family members

Castaman G, Tosetto A, Ruggeri M et al. Pseudohomozygosity for activated protein C resistance is a risk factor for venous thrombosis. Br J Haematol 99;106(1):232–6

Other reason

Chakravarty A, Hansen T S, Horder M et al. A fast and robust dual-label nonradioactive oligonucleotide ligation assay for detection of factor V Leiden. Thromb Haemost 97;78(4):1234–6

Published before 2000

Charakidas A, Brouzas D, Andrioti E et al. Papillophlebitis associated with coexisting factor V Leiden and prothrombin G20210A mutations. Retina 2002;22(2):239–40

Doesn't address study question

Cibula D, Kvasnicka J, Salaj P et al. [Informed consent for factor V Leiden mutation screening before recommending use of combined hormonal contraceptives or hormone replacement therapy ]. Ceska Gynekol 2003;68(3):212

Non-English article

Clayton E W. Ethical, legal, and social implications of genomic medicine. N Engl J Med 2003;349(6):562–9

Doesn't address study question

Cleary-Goldman J, Bettes B, Robinson J N et al. Thrombophilia and the obstetric patient. Obstet Gynecol 2007;110(3):669–74

Does not study probands or family members

Conard J, Plu-Bureau G, Bahi N et al. Progestogen-only contraception in women at high risk of venous thromboembolism. Contraception 2004;70(6):437–41

Evaluates less than 10 probands or 10 family members

Coppens M, van de, Poel M H et al. A prospective cohort study on the absolute incidence of venous thromboembolism and arterial cardiovascular disease in asymptomatic carriers of the prothrombin 20210A mutation. Blood 2006;108(8):2604–7

Other reason

Corral J, Iniesta J A, Gonzalez-Conejero R et al. Detection of factor V Leiden from a drop of blood by PCR-SSCP. Thromb Haemost 96;76(5):735–7

Published before 2000

Corral J, Zuazu-Jausoro I, Rivera J et al. Clinical and analytical relevance of the combination of prothrombin 20210A/A and factor V Leiden: results from a large family. Br J Haematol 99;105(2):560–3

No objective confirmation of VTE event

Correa M F, Rezende S M. A very rapid multiplex polymerase chain reaction for simultaneous detection of factor V Leiden and G20210A prothrombin mutation. Clin Lab Haematol 2004;26(3):239–40

Evaluates less than 10 samples

Coude M, Pineau-Vincent F. Prothombin gene: Comparative study between PCR-RFLP/Allele specific PCR: ETUDE DU GENE DE LA PROTHROMBINE: ETUDE COMPARATIVE DE DEUX TECHNIQUES PCR-RFLP/PCR ALLELES SPECIFIQUES. Immuno-Anal. Biol. Spec. 2004;19(3):177–179

Non-English article

Couturaud F, Leroyer C, Mottier D. Risk factors and clinical presentation of venous thromboembolism according to the age of relatives of patients with factor V Leiden. Thromb Haemost 2008;99(4):793–794

Case-control or retrospective cohort of family members

Dahlback B. Procoagulant and anticoagulant properties of coagulation factor V: factor V Leiden (APC resistance) causes hypercoagulability by dual mechanisms. J Lab Clin Med 99;133(5):415–22

No original data

Danneberg J, Abbes A P, Bruggeman B J et al. Reliable genotyping of the G-20210-A mutation of coagulation factor II (prothrombin). Clin Chem 98;44(2):349–51

Published before 2000

David D, Ribeiro S, Ferrao L et al. Molecular basis of inherited antithrombin deficiency in Portuguese families: identification of genetic alterations and screening for additional thrombotic risk factors. Am J Hematol 2004;76(2):163–71

Case-control or retrospective cohort of probands

De Bel A V, Van der, Cruyssen G A et al. A 2-year retrospective analysis of laboratory testing for activated protein C resistance with a factor V-corrected activated partial thromboplastin time-based method. Blood Coagul Fibrinolysis 2006;17(2):155–60

Evaluates only APC resistance

De Stefano V. Inherited thrombophilia and life-time risk of venous thromboembolism: Is the burden reducible?. J. Thromb. Haemost. 2004;2(9):1522–1525

No original data

De Stefano V, Martinelli I, Mannucci P M et al. The risk of recurrent deep venous thrombosis among heterozygous carriers of both factor V Leiden and the G20210A prothrombin mutation. N Engl J Med 99;341(11):801–6

Other reason

De Stefano V, Martinelli I, Mannucci P M et al. The risk of recurrent venous thromboembolism among heterozygous carriers of the G20210A prothrombin gene mutation. Br J Haematol 2001;113(3):630–5

Other reason

De Stefano V, Martinelli I, Rossi E et al. The risk of recurrent venous thromboembolism in pregnancy and puerperium without antithrombotic prophylaxis. Br J Haematol 2006;135(3):386–91

Other reason

Dietrich J E, Hertweck S P, Perlman S E. Efficacy of family history in determining thrombophilia risk. J Pediatr Adolesc Gynecol 2007;20(4):221–4

No objective confirmation of VTE event

Djordjevic V, Rakicevic L, Gagic M et al. Simultaneous detection of factor V Leiden and factor II G20210A variants by a multiplex PCR on whole blood. Balk. J. Med. Genet. 2001;4(1–2):15–17

Does not report concordance, discordance, or reproducibility

Dordevic V, Rakicevic L, Miljic P et al. Impact of acquired and genetic factors on thrombophilic phenotype in FV Leiden mutation carriers. Jugosl. Med. Biohem. 2005;24(2):141–146

Case-control or retrospective cohort of probands

Douketis J D, Foster G A, Crowther M A et al. Clinical risk factors and timing of recurrent venous thromboembolism during the initial 3 months of anticoagulant therapy. Arch Intern Med 2000;160(22):3431–6

Doesn't address study question

Dubreuil Lastrucci R M, Dawson D A, Bowden J H et al. Development of a simple multiplex polymerase chain reaction for the simultaneous detection of factor V Leiden and prothrombin 20210A mutations. Mol Diagn 99;4(3):247–50

Published before 2000

Dulicek P, Maly J, Safarova M. Risk of thrombosis in patients homozygous and heterozygous for factor V Leiden in the East Bohemian region. Clin Appl Thromb Hemost 2000;6(2):87–9

Doesn't address study question

Duperat V G, Fauchon M, Nurden A T et al. Simple and rapid combined genetic diagnosis of mutation (1691 G-->A) of the factor V gene and (20210 G-->A) of the prothrombin gene. Blood Coagul Fibrinolysis 98;9(6):549–51

Published before 2000

Dzhafarov T A, Rustamov R S h. [Simultaneous determination of mutations 1691 G-A of the blood coagulation system factor V gene and 20210 G-A gene, coding for prothrombin, by means of complex PCR from whole blood using one restriction enzyme (HindIII)]. Mol Biol (Mosk) 2000;34(3):486–7

Non-English article

Eichinger S, Pabinger I, Stumpflen A et al. The risk of recurrent venous thromboembolism in patients with and without factor V Leiden. Thromb Haemost 97;77(4):624–8

Other reason

Eichinger S, Weltermann A, Minar E et al. Symptomatic pulmonary embolism and the risk of recurrent venous thromboembolism. Arch Intern Med 2004;164(1):92–6

Other reason

Eikelboom J W, Ivey L, Ivey J et al. Familial thrombophilia and the prothrombin 20210A mutation: association with increased thrombin generation and unusual thrombosis. Blood Coagul Fibrinolysis 99;10(1):1–5

Evaluates less than 10 probands or 10 family members

Emmerich J, Alhenc-Gelas M, Aillaud M F et al. Clinical features in 36 patients homozygous for the ARG 506-->GLN factor V mutation. Thromb Haemost 97;77(4):620–3

Other reason

Eriksson H, Lundstrom T, Wahlander K et al. Prognostic factors for recurrence of venous thromboembolism (VTE) or bleeding during long-term secondary prevention of VTE with ximelagatran. Thromb Haemost 2005;94(3):522–7

Doesn't address study question

Faioni E M, Franchi F, Bucciarelli P et al. Coinheritance of the HR2 haplotype in the factor V gene confers an increased risk of venous thromboembolism to carriers of factor V R506Q (factor V Leiden). Blood 99;94(9):3062–6

Other reason

Favaloro E J, Bonar R, Sioufi J et al. Multilaboratory testing of thrombophilia: current and past practice in Australasia as assessed through the Royal College of Pathologists of Australasia Quality Assurance Program for Hematology. Semin Thromb Hemost 2005;31(1):49–58

Evaluates only APC resistance

Folsom A R, Cushman M, Tsai M Y et al. Prospective study of the G20210A polymorphism in the prothrombin gene, plasma prothrombin concentration, and incidence of venous thromboembolism. Am J Hematol 2002;71(4):285–90

Case-control or retrospective cohort of probands

Franco R F, Middeldorp S, Meinardi J R et al. Factor XIII Val34Leu and the risk of venous thromboembolism in factor V Leiden carriers. Br J Haematol 2000;111(1):118–21

Other reason

Friedline J A, Ahmad E, Garcia D et al. Combined factor V Leiden and prothrombin genotyping in patients presenting with thromboembolic episodes. Arch Pathol Lab Med 2001;125(1):105–11

No objective confirmation of VTE event

Gadisseur A P, Christiansen S C, VAN D E R et al. The quality of oral anticoagulant therapy and recurrent venous thrombotic events in the Leiden Thrombophilia Study. J Thromb Haemost 2007;5(5):931–6

Does not report results separately for FV Leiden and/or PT 20210A

Gancberg D, Corbisier P, Meeus N et al. Certification of reference materials for detection of the human prothrombin gene G20210A sequence variant. Clin Chem Lab Med 2008;46(4):463–9

Evaluates only DNA extraction methods

Gandrille S, Alhenc-Gelas M, Aiach M. A rapid screening method for the factor V Arg506-->Gln mutation. Blood Coagul Fibrinolysis 95;6(3):245–8

Published before 2000

Gandrille S, Remones V, Aiach M. [Validation of a diagnostic kit for factor V Leiden mutation]. Ann Biol Clin (Paris) 2003;61(6):723–7

Non-English article

Garcia-Fuster, M. J., Forner, M. J., Fernandez, C., Gil, J., Vaya, A., and Maldonado, L., Long-term prospective study of recurrent venous thromboembolism in patients younger than 50 years. Pathophysiol Haemost Thromb. 2005;34(1):6–12

Other reason

Garcia-Hernandez M C, Romero Casanova A, Marco Vera P. [Clinical comments on genetic marker prevalence (factor V Leiden, prothrombin 20210A and homozygous methylenetetrahydrofolate reductase form. Rev Clin Esp 2007;207(1):26–8

Non-English article

Gardiner C, Cooper P C, Makris M et al. An evaluation of screening tests for defects in the protein C pathway: commercial kits lack sensitivity and specificity. Blood Coagul Fibrinolysis 2002;13(2):155–63

Evaluates only APC resistance

Geisel J, Walz T, Bodis M et al. Fluorescence-based SSCP analysis with automatic allele detection demonstrated for the factor V Leiden mutation. Clin Chem 98;44(9):1986–7

Published before 2000

Ghosh K, Shetty S, Madkaikar M et al. Venous thromboembolism in young patients from western India: a study. Clin Appl Thromb Hemost 2001;7(2):158–65

Case-control or retrospective cohort of probands

Girolami A, Simioni P, Girolami B et al. G to A 20210 prothrombin polymorphism and venous thrombosis: simple association or causal relationship?. Clin Appl Thromb Hemost 2000;6(3):135–8

No original data

Girolami A, Simioni P, Girolami B et al. Low incidence of venous thrombosis in homozygous patients with NT 20210 G to a prothrombin polymorphism. Clin Appl Thromb Hemost 99;5(4):205–7

No original data

Girolami A, Tormene D, Gavasso S et al. Long term use of oral contraceptives without thrombosis in patients with FV Leiden polymorphism: a study of 37 patients (2 homozygous and 35 heterozygous). J Thromb Thrombolysis 2004;17(2):145–9

Other reason

Glynn R J, Ridker P M, Goldhaber S Z et al. Effects of random allocation to vitamin E supplementation on the occurrence of venous thromboembolism: report from the Women's Health Study. Circulation 2007;116(13):1497–503

Doesn't address study question

Golomb M R, Garg B P, Walsh L E et al. Perinatal stroke in baby, prothrombotic gene in mom: does this affect maternal health insurance?. Neurology 2005;65(1):13–6

Other reason

Gomez E, van der, Poel S C et al. Rapid simultaneous screening of factor V Leiden and G20210A prothrombin variant by multiplex polymerase chain reaction on whole blood. Blood 98;91(6):2208–9

Published before 2000

Gonzalez C M, Diaz-Golpe V, Martin S et al. Combination of congenital coagulation disorders: Factor II gene mutation G20210A, Factor V Leiden gene mutation G1691A and protein S deficiency. a family study. Haematologica 2003;88(6):ECR20

Evaluates less than 10 probands or 10 family members

Grand'Maison A, Bates S M, Johnston M et al. "ProC Global": a functional screening test that predicts recurrent venous thromboembolism. Thromb Haemost 2005;93(3):600–4

Evaluates only APC resistance

Gray E, Hawkins J R, Morrison M et al. Establishment of the 1st International Genetic Reference Panel for Factor V Leiden, human gDNA. Thromb Haemost 2006;96(2):215–9

Evaluates less than 10 samples

Greaves M, Baglin T. Laboratory testing for heritable thrombophilia: impact on clinical management of thrombotic disease annotation. Br J Haematol 2000;109(4):699–703

Doesn't address study question

Greengard J S, Xu X, Gandrille S et al. Alternative PCR method for diagnosis of mutation causing activated protein C resistant Gln506-factor V. Thromb Res 95;80(5):441–3

Published before 2000

Guillerm C, Lellouche F, Darnige L et al. Rapid detection of the G1691A mutation of coagulation factor V by PCR-mediated site-directed mutagenesis. Clin Chem 96;42(2):329

Published before 2000

Hanguehard A, Morelle M, Turchetto L et al. Genotyping in routine laboratory for detection of factor V Leiden (1691G>A) and prothrombin (20210G>A) mutations with the Invader(registered trademark) assay technology: EVALUATION EN ROUTINE D'UNE NOUVELLE METHODE POUR LE GENOTYPAGE DE LA MUTATION 1691G>A DU FACTEUR V LEIDEN ET DU VARIANT 20210G>A DU FACTEUR II PAR LA TECHNOLOGIE INVADER(registered trademark). Immuno-Anal. Biol. Spec. 2004;19(2):110–116

Non-English article

Hansson P O, Sorbo J, Eriksson H. Recurrent venous thromboembolism after deep vein thrombosis: incidence and risk factors. Arch Intern Med 2000;160(6):769–74

Doesn't address study question

Happich D, Schwaab R, Hanfland P et al. Allelic discrimination of factor V Leiden using a 5′ nuclease assay. Thromb Haemost 99;82(4):1294–6

Published before 2000

Hatzaki A, Anagnostopoulou E, Metaxa-Mariatou V et al. The impact of heterozygosity for the factor V Leiden and factor II G20210A mutations on the risk of thrombosis in Greek patients. Int Angiol 2003;22(1):79–82

Doesn't address study question

Heinemann L A, Dominh T, Assmann A et al. VTE Risk assessment - a prognostic Model: BATER Cohort Study of young women. Thromb J 2005;3(1):5

Other reason

Heldal M, Seem E, Sandset P M et al. Deep vein thrombosis: a 7-year follow-up study. J Intern Med 93;234(1):71–5

Doesn't address study question

Hellmann E A, Leslie N D, Moll S. Knowledge and educational needs of individuals with the factor V Leiden mutation. J Thromb Haemost 2003;1(11):2335–9

Less than 80% of the probands has had VTE

Herrington D M, Vittinghoff E, Howard T D et al. Factor V Leiden, hormone replacement therapy, and risk of venous thromboembolic events in women with coronary disease. Arterioscler Thromb Vasc Biol 2002;22(6):1012–7

Other reason

Hezard N, Cornillet P, Droulle C et al. Factor V Leiden: detection in whole blood by ASA PCR using an additional mismatch in antepenultimate position. Thromb Res 97;88(1):59–66

Published before 2000

Hezard N, Cornillet-Lefebvre P, Gillot L et al. Multiplex ASA PCR for a simultaneous determination of factor V Leiden gene, G-->A 20210 prothrombin gene and C-->T 677 MTHFR gene mutations. Thromb Haemost 98;79(5):1054–5

Published before 2000

Holmberg K, Persson M-L, Uhlen M et al. Pyrosequencing analysis of thrombosis-associated risk markers. Clin. Chem. 2005;51(8):1549–1552

Does not report concordance, discordance, or reproducibility

Hron G, Kollars M, Binder B R et al. Identification of patients at low risk for recurrent venous thromboembolism by measuring thrombin generation. JAMA 2006;296(4):397–402

Other reason

Hudson M, Herr A L, Rauch J et al. The presence of multiple prothrombotic risk factors is associated with a higher risk of thrombosis in individuals with anticardiolipin antibodies. J Rheumatol 2003;30(11):2385–91

Doesn't address study question

Hull R D, Pineo G F, Brant R F et al. Long-term low-molecular-weight heparin versus usual care in proximal-vein thrombosis patients with cancer. Am J Med 2006;119(12):1062–72

Other reason

Hunault M, Marsh-Scott C, Jou C et al. Automated detection of the factor V Leiden mutation using the LCx microparticle enzyme immunoassay. Clin Chem 99;45(1):41–6

Published before 2000

Huxtable L M, Tafreshi M J, Ondreyco S M. A protocol for the use of enoxaparin during pregnancy: Results from 85 pregnancies including 13 multiple gestation pregnancies. Clin. Appl. Thromb. Hemost. 2005;11(2):171–181

Doesn't address study question

Ivanov P, Komsa-Penkova R, Kovacheva K et al. Impact of thrombophilic genetic factors on pulmonary embolism: early onset and recurrent incidences. Lung 2008;186(1):27–36

Other reason

Jastrzebska M, Balszan-Kowalska I, Ciechanowicz A et al. [Activated protein C resistance, Leiden mutation, anticoagulant proteins and fibrinogen levels in patients with deep venous thrombosis]. Pol Arch Med Wewn 2003;109(6):579–88

Non-English article

Kearon C, Ginsberg J S, Anderson D R et al. Comparison of 1 month with 3 months of anticoagulation for a first episode of venous thromboembolism associated with a transient risk factor. J Thromb Haemost 2004;2(5):743–9

Other reason

Keenan C, Livingstone W J, White B et al. Prevalence of the prothrombin G20210A mutation in the Irish populations: use of a novel polymerase chain reaction approach. Blood Coagul Fibrinolysis 2000;11(7):669–72

Doesn't address study question

Kirschbaum N E, Foster P A. The polymerase chain reaction with sequence specific primers for the detection of the factor V mutation associated with activated protein C resistance. Thromb Haemost 95;74(3):874–8

Published before 2000

Klein C L, Marki-Zay J, Corbisier P et al. Reference materials (RMs) for analysis of the human factor II (prothrombin) gene G20210A mutation. Clin Chem Lab Med 2005;43(8):862–8

Does not report concordance, discordance, or reproducibility

Klingler K R, Grote S, Holzem G et al. Activated protein C (APC)-resistance: automated detection of the point mutation at position 1691 in the factor V gene. Clin Chem Lab Med 99;37(2):101–7

Published before 2000

Klingler K R, Holzem G, Wielckens K. APC-Resistance: Automated detection of the point mutation at position 1691 in the factor V gene: APC-RESISTENZ: AUTOMATISIERTER NACHWEIS DER PUNKTMUTATION AN DER POSITION 1691 IM FAKTOR V GEN. LaboratoriumsMedizin 99;23(11):606–611

Non-English article

Klingler K R, Junold T, Wielckens K. Activated protein C resistance: automated detection of the factor V Leiden mutation by mismatch hybridization. Clin Chem 99;45(11):1925–31

Published before 2000

Koizumi M, Morita K, Takagi M et al. SNP genotyping by allele-specific PCR using ENA primers. Nucleic Acids Symp Ser (Oxf) 2005;(49):47–8

Does not report concordance, discordance, or reproducibility

Kornblihtt L I, Heller P G, Correa G et al. Associated thrombophilic defects in essential thrombocythaemia: their relationship with clinical manifestations. Thromb Res 2003;112(3):131–5

Did not study venous thrombosis

Krawczak M, Cooper D N, Schmidtke J. Estimating the efficacy and efficiency of cascade genetic screening. Am J Hum Genet 2001;69(2):361–70

Doesn't address the study question

Krousel-Wood M, Andersson H C, Rice J et al. Physicians' perceived usefulness of and satisfaction with test reports for cystic fibrosis (DeltaF508) and factor V Leiden. Genet Med 2003;5(3):166–71

Doesn't address the study question

Kwiatkowski R W, Lyamichev V, de Arruda M et al. Clinical, genetic, and pharmacogenetic applications of the Invader assay. Mol Diagn 99;4(4):353–64

Published before 2000

Kwon H J, Peiper S C, Kang K A. Fiber optic immunosensors for cardiovascular disease diagnosis: quantification of Protein C, Factor V Leiden, and cardiac Troponin T in plasma. Adv Exp Med Biol 2003;510115–9

Does not report concordance, discordance, or reproducibility

Kyrle P A, Eichinger S. The risk of recurrent venous thromboembolism: the Austrian Study on Recurrent Venous Thromboembolism. Wien Klin Wochenschr 2003;115(13–14):471–4

No original data

Laczkovics C, Grafenhofer H, Kaider A et al. Risk of recurrence after a first venous thromboembolic event in young women. Haematologica 2007;92(9):1201–7

Other reason

Lapham E V, Kozma C, Weiss J O. Genetic discrimination: perspectives of consumers. Science 96;274(5287):621–4

Doesn't address study question

Lechner D, Wiener C, Weltermann A et al. Comparison between idiopathic deep vein thrombosis of the upper and lower extremity regarding risk factors and recurrence. J Thromb Haemost 2008;6(4):1269–74. Epub 2008 Apr 26

Does not report results separately for FV Leiden and/or PT 20210A

Lengyel T, Sasvari-Szekely M, Guttman A. High-throughput genotyping of factor V Leiden mutation by ultrathin-layer agarose gel electrophoresis. J Chromatogr A 99;853(1–2):519–25

Published before 2000

Lensen R P, Bertina R M, de Ronde H et al. Venous thrombotic risk in family members of unselected individuals with factor V Leiden. Thromb Haemost 2000;83(6):817–21

No objective confirmation of VTE event

Lewandowski K, Rozek M, Zawilska K et al. An alternative method for identifying the factor V gene Leiden mutation. Thromb Res 97;85(2):105–13

Published before 2000

Libourel E J, Bank I, Meinardi J R et al. Co-segregation of thrombophilic disorders in factor V Leiden carriers; the contributions of factor VIII, factor XI, thrombin activatable fibrinolysis inhibitor and lipoprotein(a) to the absolute risk of venous thromboembolism. Haematologica 2002;87(10):1068–73

Other reason

Lim W, Eikelboom J W, Ginsberg J S. Inherited thrombophilia and pregnancy associated venous thromboembolism. BMJ 2007;334(7607):1318–21

No original data

Lindqvist P G, Dahlback B. Reactions to awareness of activated protein C resistance carriership: a descriptive study of 270 women. Acta Obstet Gynecol Scand 2003;82(5):467–70

Other reason

Lindqvist P G, Olofsson P, Dahlback B. Use of selective factor V Leiden screening in pregnancy to identify candidates for anticoagulants. Obstet Gynecol 2002;100(2):332–6

Evaluates less than 10 probands or 10 family members

Linfert D R, Rezuke W N, Tsongalis G J. Rapid multiplex analysis for the factor V Leiden and prothrombin G20210A mutations associated with hereditary thrombophilia. Conn Med 98;62(9):519–25

Published before 2000

Lloyd F J, Reyna V F, Whalen P. Accuracy and ambiguity in counseling patients about genetic risk. Arch Intern Med 2001;161(20):2411–3

Doesn't address study question

Lopaciuk S, Bielska-Falda H, Noszczyk W et al. Low molecular weight heparin versus acenocoumarol in the secondary prophylaxis of deep vein thrombosis. Thromb Haemost 99;81(1):26–31

Doesn't address study question

Ludemann P, Nabavi D G, Junker R et al. Factor V Leiden mutation is a risk factor for cerebral venous thrombosis: a case-control study of 55 patients. Stroke 98;29(12):2507–10

Case-control or retrospective cohort of probands

Lutz C T, Foster P A, Noll W W et al. Multicenter evaluation of PCR methods for the detection of factor V Leiden (R506Q) genotypes. Clin Chem 98;44(6 Pt 1):1356–8

Published before 2000

Lyondagger E, Millsondagger A, Phan T et al. Detection and Identification of Base Alterations Within the Region of Factor V Leiden by Fluorescent Melting Curves. Mol Diagn 98;3(4):203–209

Published before 2000

Mahadevan M S, Benson P V. Factor V null mutation affecting the Roche LightCycler factor V Leiden assay. Clin Chem 2005;51(8):1533–5

Evaluates less than 10 samples

Maher C, Crowley D, Cullen C et al. Double fluorescent-amplification refractory mutation detection (dF-ARMS) of the factor V Leiden and prothrombin mutations. Thromb Haemost 99;81(1):76–80

Published before 2000

Makris M, Preston F E, Beauchamp N J et al. Co-inheritance of the 20210A allele of the prothrombin gene increases the risk of thrombosis in subjects with familial thrombophilia. Thromb Haemost 97;78(6):1426–9

Does not report results separately for FV Leiden and/or PT 20210A

Marcucci R, Liotta A A, Cellai A P et al. Increased plasma levels of lipoprotein(a) and the risk of idiopathic and recurrent venous thromboembolism. Am J Med 2003;115(8):601–5

Does not report results separately for FV Leiden and/or PT 20210A

Margaglione M, D'Andrea G, Colaizzo D et al. Coexistence of factor V Leiden and Factor II A20210 mutations and recurrent venous thromboembolism. Thromb Haemost 99;82(6):1583–7

Other reason

Marteau T M, Croyle R T. The new genetics. Psychological responses to genetic testing. BMJ 98;316(7132):693–6

Doesn't address study question

Martinelli I, Battaglioli T, Bucciarelli P et al. Risk factors and recurrence rate of primary deep vein thrombosis of the upper extremities. Circulation 2004;110(5):566–70

Does not report results separately for FV Leiden and/or PT 20210A

Martinelli I, Mannucci P M, De Stefano V et al. Different risks of thrombosis in four coagulation defects associated with inherited thrombophilia: a study of 150 families. Blood 98;92(7):2353–8

Other reason

McColl M D, Walker I D, Greer I A. A mutation in the prothrombin gene contributing to venous thrombosis during pregnancy. Br J Obstet Gynaecol 98;105(8):923–5

Doesn't address study question

McKenzie S B, Clare C N, Smith L A et al. Laboratory test utilization in the diagnosis of hypercoagulability. Clin Lab Sci 2000;13(4):215–21

Less than 80% of the probands has the FV Leiden or PT 20210A mutation

Medina P, Navarro S, Estelles A et al. Influence of the 4600A/G and 4678G/C polymorphisms in the endothelial protein C receptor (EPCR) gene on the risk of venous thromboembolism in carriers of factor V Leiden. Thromb Haemost 2005;94(2):389–94

Case-control or retrospective cohort of probands

Meinardi J R, Middeldorp S, de Kam P J et al. Risk of venous thromboembolism in carriers of factor V Leiden with a concomitant inherited thrombophilic defect: a retrospective analysis. Blood Coagul Fibrinolysis 2001;12(8):713–20

Other reason

Meltzer M E, Lisman T, Doggen C J et al. Synergistic Effects of Hypofibrinolysis and Genetic and Acquired Risk Factors on the Risk of a First Venous Thrombosis. PLoS Med 2008;5(5):e97

Case-control or retrospective cohort of probands

Meyer M, Kutscher G, Vogel G. Simultaneous genotyping for factor V Leiden and prothrombin G20210A variant by a multiplex PCR-SSCP assay on whole blood. Thromb Haemost 99;81(1):162–3

Published before 2000

Minano A, Ordonez A, Espana F et al. AB0 blood group and risk of venous or arterial thrombosis in carriers of factor V Leiden or prothrombin G20210A polymorphisms. Haematologica 2008;93(5):729–34

Case-control or retrospective cohort of probands

Misgav M, Eldor A, Berliner S. [A new mutation in the prothrombin gene (G20210A) and the risk for venous and arterial thromboembolism]. Harefuah 2000;139(1–2):51–6

Non-English article

Mitterer M, Lanthaler A J, Mair W et al. Simultaneous detection of FV Q506 and prothrombin 20210 A variation by allele-specific PCR. Haematologica 99;84(3):204–7

Published before 2000

Moll S, Escobar M. Prothrombin and factor V mutations in women with a history of thrombosis during pregnancy and the puerperium. N Engl J Med 2000;342(26):1996–7

Doesn't address study question

Muriel G, Christine B, Philippe J et al. An even easier method for one-step detection of both FV Leiden and FII G20210A transition. Blood 98;92(9):3478–9

Published before 2000

Murphy K M, Eshleman J R. Simultaneous sequencing of multiple polymerase chain reaction products and combined polymerase chain reaction with cycle sequencing in single reactions. Am J Pathol 2002;161(1):27–33

Does not report concordance, discordance, or reproducibility

Murphy K M, Berg K D, Eshleman J R. Sequencing of genomic DNA by combined amplification and cycle sequencing reaction. Clin Chem 2005;51(1):35–9

Evaluates only DNA extraction methods

Mustafa S, Mannhalter C, Rintelen C et al. Clinical features of thrombophilia in families with gene defects in protein C or protein S combined with factor V Leiden. Blood Coagul Fibrinolysis 98;9(1):85–9

No objective confirmation of VTE event

Nagy P L, Schrijver I, Zehnder J L. Molecular Diagnosis of Hypercoagulable States. Lab. Med. 2004;35(4):214–221

No original data

Naudziunas A, Miliauskas S. Factor V Leiden and post thromboembolic pulmonary hypertension. Medicina (Kaunas) 2003;39(12):1171–4

Did not study venous thrombosis

Navarro S, Medina P, Mira Y et al. Haplotypes of the EPCR gene, prothrombin levels, and the risk of venous thrombosis in carriers of the prothrombin G20210A mutation. Haematologica 2008;93(6):885–91. Epub 2008 Apr 9

Case-control or retrospective cohort of probands

Neoh S H, Brisco M J, Firgaira F A et al. Rapid detection of the factor V Leiden (1691 G > A) and haemochromatosis (845 G > A) mutation by fluorescence resonance energy transfer (FRET) and real time PCR. J Clin Pathol 99;52(10):766–9

Published before 2000

Noboa S, Le Gal G, Lacut K et al. Family history as a risk factor for venous thromboembolism. Thromb Res 2008;122(5):624–9. Epub 2008 Feb 20

Does not report results separately for FV Leiden and/or PT 20210A

Oguzulgen I K, Demirtas S, Erkekol F O et al. The Role of Plasminogen Activator Inhibitor-1 Polymorphism, Factor-V-Leiden, and Prothrombin-20210 Mutations in Pulmonary Thromboembolism. Clin Appl Thromb Hemost 2007;[Epub ahead of print]

Case-control or retrospective cohort of probands

Oguzulgen I K, Ekim N N, Akar N et al. The role of thrombophilic risk factors in the severity of pulmonary thromboembolism. Eur Respir J 2002;19(4):709–11

Doesn't address study question

Olds R J, Fitches A C, Geary C P. The multigenic basis for venous thrombosis. Br J Haematol 2000;109(3):508–11

No original data

Orum H, Jakobsen M H, Koch T et al. Detection of the factor V Leiden mutation by direct allele-specific hybridization of PCR amplicons to photoimmobilized locked nucleic acids. Clin Chem 99;45(11):1898–905

Published before 2000

Otterson G A, Monahan B P, Harold N et al. Clinical significance of the FV:Q506 mutation in unselected oncology patients. Am J Med 96;101(4):406–12

Evaluates less than 10 probands or 10 family members

Pabinger I, Grafenhofer H, Kaider A et al. Risk of pregnancy-associated recurrent venous thromboembolism in women with a history of venous thrombosis. J Thromb Haemost 2005;3(5):949–54

Other reason

Palareti G, Cosmi B, Legnani C et al. D-dimer testing to determine the duration of anticoagulation therapy. N Engl J Med 2006;355(17):1780–9

Other reason

Palareti G, Legnani C, Cosmi B et al. Poor anticoagulation quality in the first 3 months after unprovoked venous thromboembolism is a risk factor for long-term recurrence. J Thromb Haemost 2005;3(5):955–61

Doesn't address study question

Paolo, G., Marco, C., Silvia, M., Alessandra, V., Fabbio, M., Nicoletta, C., Giorgio, F., Carlo Federico, P., and Sergio, B. Impact of storage conditions on genetic analysis or viral load determination in clinical specimens. Clin Chem Lab Med, 2007;[Epub ahead of print]

Doesn't address study question

Paschoa A F, Guillaumon A T. Impact of screening on thrombophilia for patients with venous thrombosis. Int Angiol 2006;25(1):52–9

Other reason

Patri S, Salmeron S, Caillon M et al. Multiplex PCR for one-step determination of the G20210A variation and the factor V Leiden mutation by denaturing gradient gel electrophoresis (DGGE). Thromb Haemost 99;81(2):313–4

Published before 2000

Patrushev L I, Zykova E S, Kayushin A L et al. New DNA diagnostic system for detection of factor V Leiden. Thromb Res 98;92(6):251–9

Published before 2000

Pecheniuk N M, Marsh N A, Walsh T P et al. Use of first nucleotide change technology to determine the frequency of factor V Leiden in a population of Australian blood donors. Blood Coagul Fibrinolysis 97;8(8):491–5

Published before 2000

Peng F, Triplett D, Barna L. Direct PCR of leukocytes treated with microwave irradiation to detect factor V Leiden mutation. Thromb Res 96;82(2):193–7

Published before 2000

Pernod G, Mossuz P, Polack B. Optimized factor V gene mutation detection using buffy-coat direct PCR. Biotechniques 97;22(5):837, 840, 841

Published before 2000

Pettila V, Kaaja R, Leinonen P et al. Thromboprophylaxis with low molecular weight heparin (dalteparin) in pregnancy. Thromb Res 99;96(4):275–82

Doesn't address study question

Pini M, Aiello S, Manotti C et al. Low molecular weight heparin versus warfarin in the prevention of recurrences after deep vein thrombosis. Thromb Haemost 94;72(2):191–7

Doesn't address study question

Prandoni P, Lensing A W, Piccioli A et al. Recurrent venous thromboembolism and bleeding complications during anticoagulant treatment in patients with cancer and venous thrombosis. Blood 2002;100(10):3484–8

Doesn't address study question

Prandoni P, Lensing A W, Prins M H et al. Residual venous thrombosis as a predictive factor of recurrent venous thromboembolism. Ann Intern Med 2002;137(12):955–60

Doesn't address study question

Press R D. Thrombophilic mutations impart a high risk of pregnancy-related venous thrombosis. Mol Diagn 2000;5(2):158

Doesn't address study question

Quehenberger P, Handler S, Mannhalter C et al. The Factor V (Leiden) test: evaluation of an assay based on dilute Russell Viper Venom Time for the detection of the Factor V Leiden mutation. Thromb Res 99;96(2):125–33

Published before 2000

Raoul M, Mathonnet F, Peltier J Y et al. An improved method for the detection of the G20210A transition in the prothrombin gene. Thromb Res 97;88(5):441–3

Published before 2000

Reitsma P H, van der, Velden P A et al. Use of the direct RNA amplification technique NASBA to detect factor V Leiden, a point mutation associated with APC resistance. Blood Coagul Fibrinolysis 96;7(6):659–63

Published before 2000

Ren, Y., Rezania, S., and Kang, K. A. Biosensor for diagnosing Factor V Leiden, a single amino acid mutated abnormality of Factor V. Adv Exp Med Biol 2008;614:245–52

Other reason

Ridker P M, Goldhaber S Z, Danielson E et al. Long-term, low-intensity warfarin therapy for the prevention of recurrent venous thromboembolism. N Engl J Med 2003;348(15):1425–34

Other reason

Rintelen C, Mannhalter C, Lechner K et al. No evidence for an increased risk of venous thrombosis in patients with factor V Leiden by the homozygous 677 C to T mutation in the methylenetetrahydrofolate-reductase gene. Blood Coagul Fibrinolysis 99;10(2):101–5

Does not report results separately for FV Leiden and/or PT 20210A

Rintelen C, Pabinger I, Knobl P et al. Probability of recurrence of thrombosis in patients with and without factor V Leiden. Thromb Haemost 96;75(2):229–32

Other reason

Robert A, Aillaud M F, Eschwege V et al. ABO blood group and risk of venous thrombosis in heterozygous carriers of factor V Leiden. Thromb Haemost 2000;83(4):630–1

Doesn't address study question

Rodeghiero F, Tosetto A. The epidemiology of inherited thrombophilia: the VITA Project. Vicenza Thrombophilia and Atherosclerosis Project. Thromb Haemost 97;78(1):636–40

Doesn't address study question

Ruggeri M, Gisslinger H, Tosetto A et al. Factor V Leiden mutation carriership and venous thromboembolism in polycythemia vera and essential thrombocythemia. Am J Hematol 2002;71(1):1–6

Other reason

Russeva M G, Janakiev P J, Kirov S A et al. A simple method for detection of factor V R506Q (Leiden) mutation in dried blood spots. Clin Chim Acta 99;284(1):89–92

Published before 2000

Ryan D, Nuccie B, Arvan D. Non-PCR-dependent detection of the factor V Leiden mutation from genomic DNA using a homogeneous invader microtiter plate assay. Mol Diagn 99;4(2):135–44

Published before 2000

Sabbagh A S, Ibrahim G, Kanaan Z et al. Prevalence of the prothrombin G20210A polymorphism in the Lebanese population: use of a reverse hybridization strip assay approach. Mol Biol Rep 2007;[Epub ahead of print]

Does not report concordance, discordance, or reproducibility

Saffroy R, Lemoine A, Haas P et al. Rapid automated simultaneous screening of (G1691A) Factor V, (G20210A) prothrombin, and (C677T) methylenetetrahydrofolate reductase variants by multiplex PCR using fluorescence scanning technology. Genet Test 2002;6(3):233–6

Does not report concordance, discordance, or reproducibility

Samama M M, Rached R A, Conard J et al. [Pregnancy-associated venous thrombosis in women with hereditary heterozygous factor V Leiden and/or factor II gene mutations]. Bull Acad Natl Med 2004;188(8):1377–93; discussion 1393–6

Non-English article

Samama M-M, Rached R A, Conard J et al. Pregnancy-associated venous thrombosis in women with hereditary heterozygous factor V Leiden and/or factor II gene mutations: RISQUE DE THROMBOSE LIE A LA GROSSESSE CHEZ LES FEMMES PORTEUSES D'UNE MUTATION HETEROZYGOTE DU FACTEUR V LEIDEN, DU FACTEUR II OU DE LEUR ASSOCIATION. Bull. Acad. Natl. Med. 2004;188(8):1377–1396

Non-English article

Santamaria A, Mateo J, Oliver A et al. Risk of thrombosis associated with oral contraceptives of women from 97 families with inherited thrombophilia: high risk of thrombosis in carriers of the G20210A mutation of the prothrombin gene. Haematologica 2001;86(9):965–71

Other reason

Sasvari-Szekely M, Gerstner A, Ronai Z et al. Rapid genotyping of factor V Leiden mutation using single-tube bidirectional allele-specific amplification and automated ultrathin-layer agarose gel electrophoresis. Electrophoresis 2000;21(4):816–21

Does not report concordance, discordance, or reproducibility

Scharnhorst V, Gijselhart-Nivillac N J F, Goorhuis A D et al. Detection of factor V Leiden and factor II mutations by using duplex PCR: DETECTIE VAN DE FACTOR-V-LEIDEN- EN FACTOR-II-MUTATIES MET BEHULP VAN EEN DUPLEX-PCR. Ned. Tijdschr. Klin. Chem. Lab. Geneeskd. 2004;29(1):33–35

Non-English article

Schattner A, Kasher I, Berrebi A. Causes and outcome of deep-vein thrombosis in otherwise-healthy patients under 50 years. QJM 97;90(4):283–7

Does not report results separately for FV Leiden and/or PT 20210A

Schramm W, Heinemann L A, Spannagl M et al. [The Bavarian Thromboembolic Risk Cohort Study (BATER). Study protocol, state of the investigation and first results]. Dtsch Med Wochenschr 2000;125(1–2):2–6

Non-English article

Schroder W, Koesling M, Wulff K et al. Large-scale screening for factor V Leiden mutation in a north-eastern German population. Haemostasis 96;26(5):233–6

Published before 2000

Schulman S, Granqvist S, Holmstrom M et al. The duration of oral anticoagulant therapy after a second episode of venous thromboembolism. The Duration of Anticoagulation Trial Study Group. N Engl J Med 97;336(6):393–8

Doesn't address study question

Schulman S, Lindmarker P, Holmstrom M et al. Post-thrombotic syndrome, recurrence, and death 10 years after the first episode of venous thromboembolism treated with warfarin for 6 weeks or 6 months. J Thromb Haemost 2006;4(4):734–42

Other reason

Schulman S, Wahlander K, Lundstrom T et al. Secondary prevention of venous thromboembolism with the oral direct thrombin inhibitor ximelagatran. N Engl J Med 2003;349(18):1713–21

Doesn't address study question

Scobie G A, Ho S T, Dolan G et al. Development of a rapid DNA screening procedure for the Factor V Leiden mutation. Clin Mol Pathol 96;49(6):M361–M363

Published before 2000

Shrivastava S, Ridker P M, Glynn R J et al. D-dimer, factor VIII coagulant activity, low-intensity warfarin and the risk of recurrent venous thromboembolism. J Thromb Haemost 2006;4(6):1208–14

Doesn't address study question

Simioni P, Prandoni P, Lensing A W et al. The risk of recurrent venous thromboembolism in patients with an Arg506-->Gln mutation in the gene for factor V (factor V Leiden). N Engl J Med 97;336(6):399–403

Other reason

Simkova M, Batorova A, Dostalova K et al. Factor V Leiden in patients with venous thrombosis in Slovak population. Gen Physiol Biophys 2004;23(4):435–42

Doesn't address study question

Sinclair G D, Low S, Poon M C. A hemi-nested, allele specific, whole blood PCR assay for the detection of the factor V Leiden mutation. Thromb Haemost 97;77(6):1154–5

Published before 2000

Sitbon G, Hurtig M, Palotie A et al. A colorimetric minisequencing assay for the mutation in codon 506 of the coagulation factor V gene. Thromb Haemost 97;77(4):701–3

Published before 2000

Snyder T M, McGown L B. Multiplex single strand conformation polymorphism analysis by capillary electrophoresis with on-the-fly fluorescence lifetime detection. Appl Spectrosc 2005;59(3):335–9

Does not report concordance, discordance, or reproducibility

Solem C A, Loftus E V, Tremaine W J et al. Venous thromboembolism in inflammatory bowel disease. Am J Gastroenterol 2004;99(1):97–101

Doesn't address study question

Souto J C, Mateo J, Soria J M et al. Homozygotes for prothrombin gene 20210 A allele in a thrombophilic family without clinical manifestations of venous thromboembolism. Haematologica 99;84(7):627–32

Did not study venous thrombosis

Sproul A M, Chalmers E A. Multiplex PCR for the detection of the factor V Leiden and prothrombin 20210A mutations. Methods Mol Med 2004;9179–87

Does not report concordance, discordance, or reproducibility

Srur A E, Vargas R C, Salas F S et al. Primary thombophilia. Report of 93 cases and 12 asymptomatic relatives: TROMBOFILIA PRIMARIA: DETECCION Y MANIFESTACION CLINICA EN 105 CASOS. Rev. Med. Chile 2004;132(12):1466–1473

Non-English article

Stegnar M, Peternel P, Uhrin P et al. Fibrinolysis in patients with the 1691 G->A mutation in factor V gene and history of deep vein thrombosis. FIBRINOLYSIS PROTEOLYSIS 97;11(4):201–207

Doesn't address study question

Strobl F J, Hoffman S, Huber S et al. Activated protein C resistance assay performance: improvement by sample dilution with factor V-deficient plasma. Arch Pathol Lab Med 98;122(5):430–3

Published before 2000

Tirado I, Mateo J, Soria J M et al. Contribution of prothrombin 20210A allele and factor V Leiden mutation to thrombosis risk in thrombophilic families with other hemostatic deficiencies. Haematologica 2001;86(11):1200–8

Other reason

Tormene D, Fortuna S, Tognin G et al. The incidence of venous thromboembolism in carriers of antithrombin, protein C or protein S deficiency associated with the HR2 haplotype of factor V: a family cohort study. J Thromb Haemost 2005;3(7):1414–20

Doesn't address study question

Tormene D, Simioni P, Prandoni P et al. The risk of fetal loss in family members of probands with factor V Leiden mutation. Thromb Haemost 99;82(4):1237–9

Published before 2000

Tosetto A, Missiaglia E, Frezzato M et al. The VITA project: prothrombin G20210A mutation and venous thromboembolism in the general population. Thromb Haemost 99;82(5):1395–8

Case-control or retrospective cohort of probands

Toulon P, Lequerrec A, Piquet P et al. Significant influence of the instrument on the result of the ProC Global assay. A multicenter evaluation using lyophilized plasmas and frozen plasma samples from carriers and non-carriers of the factor V Leiden mutation. Thromb Res 2002;107(3–4):181–8

Evaluates only APC resistance

Tran M, Spencer F A. Thromboepidemiology: identifying patients with heritable risk for thrombin-mediated thromboembolic events. Am Heart J 2005;149(1 Suppl):S9–18

No original data

Uitte de, Willige S, De Visser M C et al. Selectin haplotypes and the risk of venous thrombosis: influence of linkage disequilibrium with the factor V Leiden mutation. J Thromb Haemost 2008;6(3):478–85

Case-control or retrospective cohort of probands

Ulvik A, Ren J, Refsum H et al. Simultaneous determination of methylenetetrahydrofolate reductase C677T and factor V G1691A genotypes by mutagenically separated PCR and multiple-injection capillary electrophoresis. Clin Chem 98;44(2):264–9

Published before 2000

van Boven H H, Vandenbroucke J P, Briet E et al. Gene-gene and gene-environment interactions determine risk of thrombosis in families with inherited antithrombin deficiency. Blood 99;94(8):2590–4

Does not report results separately for FV Leiden and/or PT 20210A

van de, Locht L T, Kuypers A W et al. Semi-automated detection of the factor V mutation by allele specific amplification and capillary electrophoresis. Thromb Haemost 95;74(5):1276–9

Published before 2000

van der, Meer F J, Koster T et al. The Leiden Thrombophilia Study (LETS). Thromb Haemost 97;78(1):631–5

No original data

van Hylckama, Vlieg A, Baglin C A et al. Proof of principle of potential clinical utility of multiple SNP analysis for prediction of recurrent venous thrombosis. J Thromb Haemost 2008;6(5):751–4

Other reason

Van Rooijen M, Bremme K. A family history can display a synergistic effect of atherogenic and prothrombotic risk in pregnancy. Acta Obstet Gynecol Scand 2001;80(9):873–4

Doesn't address study question

Vandenbroucke J P, Briet E, Helmerhorst F et al. [Oral contraception increases the chance of venous thrombosis in factor V Leiden mutation]. Ned Tijdschr Geneeskd 95;139(21):1067–71

Non-English article

Varga Elizabeth A, Moll Stephan. Prothrombin 20210 Mutation (Factor II Mutation). Circulation 2004;110(3):e15–18

No original data

Vatan R, Delpeu K, Vergnes C et al. [Clinicobiological study of 100 symptomatic patients with factor V Leiden mutation]. Rev Med Interne 2000;21(5):465–6

Non-English article

Veiga F, Escriba A, Maluenda M P et al. Low molecular weight heparin (enoxaparin) versus oral anticoagulant therapy (acenocoumarol) in the long-term treatment of deep venous thrombosis in the elderly: a randomized trial. Thromb Haemost 2000;84(4):559–64

Doesn't address study question

Voelkerding K V, Huber S, Strobl F et al. Resistance to Activated Protein C: Comparison of Three Different PCR Methods for Detection FV R506Q. Mol Diagn 96;1(4):297–304

Published before 2000

von Ahsen N, Oellerich M, Schutz E. A method for homogeneous color-compensated genotyping of factor V (G1691A) and methylenetetrahydrofolate reductase (C677T) mutations using real-time multiplex fluorescence PCR. Clin Biochem 2000;33(7):535–9

Does not report concordance, discordance, or reproducibility

von Ahsen N, Oellerich M, Armstrong V W et al. Application of a thermodynamic nearest-neighbor model to estimate nucleic acid stability and optimize probe design: prediction of melting points of multiple mutations of apolipoprotein B-3500 and factor V with a hybridization probe genotyping assay on the LightCycler. Clin Chem 99;45(12):2094–101

Published before 2000

von Ahsen N, Schutz E, Armstrong V W et al. Rapid detection of prothrombotic mutations of prothrombin (G20210A), factor V (G1691A), and methylenetetrahydrofolate reductase (C677T) by real-time fluorescence PCR with the LightCycler. Clin Chem 99;45(5):694–6

Does not report concordance, discordance, or reproducibility

Walz T, Geisel J, Bodis M et al. Fluorescence-based single-strand conformation polymorphism analysis of mutations by capillary electrophoresis. Electrophoresis 2000;21(2):375–9

Does not report concordance, discordance, or reproducibility

Welbourn J T, Maiti S, Paley J. Factor V Leiden detection by polymerase chain reaction-restriction fragment length polymorphism with mutagenic primers in a multiplex reaction with Pro G20210A--a novel technique. Hematology 2003;8(2):73–5

Does not report concordance, discordance, or reproducibility

Weltermann A, Eichinger S, Bialonczyk C et al. The risk of recurrent venous thromboembolism among patients with high factor IX levels. J Thromb Haemost 2003;1(1):28–32

Other reason

White R H, Chan W S, Zhou H et al. Recurrent venous thromboembolism after pregnancy-associated versus unprovoked thromboembolism. Thromb Haemost 2008;100(2):246–52

Doesn't address study question

Wilde J T, O'Sullivan J J, Roper J L et al. A novel ELISA-based primer extension assay for the detection of the factor V Leiden mutation. Br J Haematol 99;106(2):427–30

Published before 2000

Wisotzkey J D, Bell T, Monk J S. Simultaneous polymerase chain reaction restriction fragment length polymorphism identification of the factor V Leiden allele and the prothrombin 20210A mutation. Diagn Mol Pathol 98;7(3):180–3

Published before 2000

Wong T, Nightingale J, Winter M et al. Spontaneous venous thrombosis in inflammatory bowel disease: relevance of factor V Leiden and the prothrombin gene mutation. J Thromb Haemost 2003;1(6):1326–8

Doesn't address study question

Xu X, Bauer K A, Griffin J H. Two multiplex PCR-based DNA assays for the thrombosis risk factors prothrombin G20210A and coagulation factor V G1691A polymorphisms. Thromb Res 99;93(6):265–9

Does not report concordance, discordance, or reproducibility

Yandava C N, Zappulla D C, Korf B R et al. ARMS test for diagnosis of factor VLeiden mutation, a common cause of inherited thrombotic tendency. J Clin Lab Anal 96;10(6):414–7

Published before 2000

Young L, Ockelford P, Milne D et al. Post-treatment residual thrombus increases the risk of recurrent deep vein thrombosis and mortality. J Thromb Haemost 2006;4(9):1919–24

Doesn't address study question

Zehnder J L, Benson R C, Cheng S. A microplate allele-specific oligonucleotide hybridization assay for detection of factor V Leiden. Diagn Mol Pathol 97;6(6):347–52

Published before 2000

Zehnder J, Van Atta R, Jones C et al. Cross-linking hybridization assay for direct detection of factor V Leiden mutation. Clin Chem 97;43(9):1703–8

Published before 2000

Zotz R B, Maruhn-Debowski B, Scharf R E. Mutation in the gene coding for coagulation factor V and resistance to activated protein C: detection of the genetic mutation by oligonucleotide ligation assay using a semi-automated system. Thromb Haemost 96;76(1):53–5

Published before 2000