# Detailed Search Strategies

Database | Terms | Date | Returns
PubMed | (((Inherit*[tiab] OR herit*[tiab] OR genetic*[tiab] OR genotype[tiab] OR familial[tiab]) AND (thrombophil*[tiab] OR coagula*[tiab] OR (venous[tiab] AND (thromboemboli*[tiab] OR thrombophili*[tiab])) OR "deep vein thrombosis"[tiab] OR "deep-vein thrombosis"[tiab] OR "deep venous thrombosis"[tiab] OR VTE[tiab] OR “pulmonary embolism”[tiab])) OR ("factor v/genetics"[mh] OR ("factor v"[tiab] AND (leiden[tiab] OR g1691a[tiab] OR Arg506[tiab] OR R506Q[tiab] OR (ARG[tiab] AND 506[tiab]))) OR "prothrombin/genetics"[mh] OR (prothrombin[tiab] AND (G20210A[tiab] OR 20210[tiab] OR 20210GA[tiab])))) AND 1993:2008[dp] NOT (animals[mh] NOT humans[mh]) NOT (editorial[pt] OR comment[pt] OR letter[pt]) | 5/9/08 | 5704
EMBASE | (((Inherit*:ti,ab OR herit*:ti,ab OR genetic*:ti,ab OR genotype:ti,ab OR familial:ti,ab) AND (thrombophil*:ti,ab OR coagula*:ti,ab OR (venous:ti,ab AND (thromboemboli*:ti,ab OR thrombophili*:ti,ab)) OR "deep vein thrombosis":ti,ab OR "deep-vein thrombosis":ti,ab OR "deep venous thrombosis":ti,ab OR VTE:ti,ab OR “pulmonary embolism”:ti,ab)) OR (‘blood clotting factor v leiden’/exp OR ("factor v":ti,ab AND (leiden:ti,ab OR g1691a:ti,ab OR Arg506:ti,ab OR R506Q:ti,ab OR (ARG:ti,ab AND 506:ti,ab))) OR ((prothrombin/exp OR prothrombin:ti,ab) AND (G20210A:ti,ab OR 20210:ti,ab OR 20210GA:ti,ab)))) AND [1993–2008]/py NOT ([conference paper]/lim OR [editorial]/lim OR [erratum]/lim OR [letter]/lim OR [note]/lim) NOT ([animals]/lim NOT [humans]/lim) | 5/12/08 | 6297
Cochrane Library | (((Inherit*:ti,ab OR herit*:ti,ab OR genetic*:ti,ab OR genotype:ti,ab OR familial:ti,ab) AND (thrombophil*:ti,ab OR coagula*:ti,ab OR (venous:ti,ab AND (thromboemboli*:ti,ab OR thrombophili*:ti,ab)) OR "deep vein thrombosis":ti,ab OR "deep-vein thrombosis":ti,ab OR "deep venous thrombosis":ti,ab OR VTE:ti,ab OR “pulmonary embolism”:ti,ab)) OR (“factor v”:genetics[mh] OR ("factor v":ti,ab AND (leiden:ti,ab OR g1691a:ti,ab OR Arg506:ti,ab OR R506Q:ti,ab OR (ARG:ti,ab AND 506:ti,ab))) OR "prothrombin:genetics"[mh] OR (prothrombin[tiab] AND (G20210A[tiab] OR 20210[tiab] OR 20210GA[tiab])))), from 1993 to 2008 | 5/12/08 | 129 Cochrane reviews 7 DARE 3 CENTRAL 108 Economic Evaluation s 5
PsycInfo | (((AB Inherit* OR AB herit* OR AB genetic* OR AB genotype OR AB familial) AND (AB thrombophil* OR AB coagula* OR (AB venous AND (AB thromboemboli* OR AB thrombophili*)) OR AB "deep vein thrombosis" OR AB "deep-vein thrombosis" OR AB "deep venous thrombosis" OR AB VTE)) OR ((TI “factor V” OR AB "factor v") AND (AB leiden OR AB g1691a OR AB Arg506 OR AB R506Q OR (AB ARG AND AB 506))) OR ((TI prothrombin OR AB prothrombin) AND (AB G20210A OR AB 20210 OR AB 20210GA))) AND DT 199301-200812 NOT (PZ animal NOT PZ human) Not ((ZZ "BIBLIOGRAPHY") or (ZZ "CHAPTER") or (ZZ "COLUMN/OPINION") or (ZZ "COMMENT/REPLY") or (ZZ "EDITORIAL") or (ZZ "ENCYCLOPEDIA ENTRY") or (ZZ "LETTER") or (ZZ "OBITUARY") or (ZZ "PUBLICATION INFORMATION")) | 5/12/08 | 25
CINAHL | (((TX Inherit* OR TX herit* OR TX genetic* OR TX genotype OR TX familial) AND (TX thrombophil* OR TX coagula* OR (TX venous AND (TX thromboemboli* OR TX thrombophili*)) OR TX "deep vein thrombosis" OR TX "deep-vein thrombosis" OR TX "deep venous thrombosis" OR TX VTE)) OR ((TI “factor V” OR TX "factor v") AND (TX leiden OR TX g1691a OR TX Arg506 OR TX R506Q OR (TX ARG AND TX 506))) OR ((TI prothrombin OR TX prothrombin) AND (TX G20210A OR TX 20210 OR TX 20210GA))) AND (PY 1993–2008) AND (ZT "CLINICAL TRIAL" or ZT "JOURNAL ARTICLE" or ZT "RESEARCH" or ZT "REVIEW" or ZT "SYSTEMATIC REVIEW") | 5/12/08 | 660