# Hand Searched Journals

Clinical Chemistry

British Journal of Haematology

Thrombosis and Heamostasis

Blood Coagulation and Fibrinolysis

Journal of Thrombosis and Haemostasis

Thrombosis Research

Molecular and Cellular Probes

Haematologica

NEJM

Blood

Annals of Internal Medicine