# Technical Experts and Peer Reviewers

- Frederick Chen, M.D., M.P.H., F.A.A.F.P.
- Department of Family Medicine
- University of Washington
- Seattle, WA

- William Gregory Feero, M.D., Ph.D.
- National Human Genome Research Institute
- National Institutes of Health
- Bethesda, MD

- Andrea Ferreira-Gonzalez, Ph.D.
- Virginia Commonwealth University
- Richmond, VA

- Steven Gutman, M.D.
- Office of In Vitro Diagnostic Device
- Evaluation and Safety
- Center for Devices and Radiological Health
- Food and Drug Administration
- U.S. Department of Health and Human Services
- Washington, DC

- James Haddow, M.D.
- Director, Division of Medical Screening
- Women and Infants' Hospital
- Providence, RI

- Denise L. Heaney, Ph.D.
- Roche Diagnostics Corporation
- Dept. of Medical and Scientific Affairs
- Indianapolis, IN

- John Heit, M.D.
- Division of Cardiovascular Diseases
- Department of Internal Medicine
- Mayo Clinic
- Rochester, MN

- Clive Kearon, M.D., Ph.D.
- Professor of Medicine, McMaster University
- Head, Clinical Thrombosis Service
- Henderson General Hospital
- Hamilton, CA

- Lori Preston, M.B.A.
- Vice President of National Alliance for
- Thrombosis and Thrombophila
- Towson, MD

- Sue Richards, Ph.D., F.A.C.M.G.
- Professor, Molecular & Medical Genetics
- Scientific Director, Molecular Diagnostic Center
- Oregon Health & Science University
- Portland, OR

- Steven Teutsch, M.D., M.P.H.
- Executive Director of Outcomes Research
- Merck & Co.
- West Point, PA

- Elizabeth Varga, M.S., C.G.C.
- Molecular and Human Genetics
- Columbus Children's Research Institute
- Columbus, OH

- Marc S. Williams, M.D., F.A.A.P., F.AC.M.G.
- Intermountain Healthcare Clinical Genetics Institute
- Salt Lake City, UT